# Surgeon General's Workshop Participant List

Randy Alexander, M.D., Ph.D. Chief Division of Child Protection and Forensic Pediatrics University of Florida 1650 Prudential Drive, Suite 100 Jacksonville, FL 32207 Phone: (904) 265-4900 Email: ralexander@abusenet.org | Sharon Amatetti, M.P.H. Senior Public Health Analyst Substance Abuse and Mental Health Services Administration 1 Choke Cherry Road, Room 5-1-039 Rockville, MD 20850 Phone: (240) 276-1694 Email: haron.amatetti@samhsa.hhs.gov
Lisa Bain Executive Editor Parenting Magazine Parenting Group 530 Fifth Avenue New York, NY 10036 Phone: (212) 522-8518 Email: lisa_bain@timeinc.com | Megan Bair-Merritt, M.D. General Pediatric Fellow Department of Pediatrics Children's Hospital of Philadelphia 3535 Market Street, Office 1550 Philadelphia, PA 19104 Phone: (215) 590-2174 Email: merritt@email.chop.edu
Kirsten Bechtel, M.D. Assistant Professor of Pediatric Emergency Medicine Department of Pediatrics Yale University 333 Cedar Street New Haven, CT 06520-8064 Phone: (203) 688-4936 Email: kirsten.bechtel@yale.edu | Judith Becker, Ph.D. Professor Department of Psychology University of Arizona 1503 East University P.O. Box 210068 Tucson, AZ 85721 Phone: (520) 621-7455 Email: jvbecker@u.arizona.edu
Katherine Beckmann Emerging Leader National Institute of Child Health and Human Development National Institutes of Health Phone: (301) 435-3458 Email: katherine.beckmann@hhs.gov | Carol Berkowitz, M.D. President American Academy of Pediatrics 141 Northwest Point Boulevard Elk Grove Village, IL 60007 Phone: (847) 434-4000 Email: carolb@pol.net
Shay Bilchik, J.D. President/CEO Child Welfare League of America 440 First Street, N.W., 3rd Floor Washington, DC 20001-2085 Phone: (202) 638-2952 Email: sbilchik@cwla.org | Thomas Birch, J.D. Legislative Counsel National Child Abuse Coalition 733 15th Street, N.W., Suite 938 Washington, DC 20005 Phone: (202) 347-3666 Email: tbirch@elinkisp.com
Barbara Bonner, Ph.D., M.Ed. Director of the Center on Child Abuse and Neglect Department of Pediatrics University of Oklahoma Health Sciences Center 940 N.E. 13th Street Oklahoma City, OK 73104 Phone: (405) 271-4401 Email: barbara-bonner@ouhsc.edu | Cheryl Boyce, Ph.D. Program Chief Child Abuse and Neglect Program National Institute of Mental Health National Institutes of Health 6001 Executive Boulevard, Room 6300 Bethesda, MD 20892 Phone: (301) 443-0848 Email: cboyce@mail.nih.gov
CAPT Stephanie Bryn, M.P.H. Health Resources and Services Administration 5600 Fishers Lane Parklawn Building, Room 18A-38 Rockville, MD 20857 Phone: (301) 443-6091 Email: sbryn@hrsa.gov | Jim Bueermann, M.B.A. Chief of Police and Community Services City of Redlands 35 Cajon Street Redlands, CA 92373 Phone: (909) 798-7661 Email: jbueermann@aol.com
Ann Burgess, Ph.D., R.N., FAAN Professor of Psychiatric Mental Health Nursing School of Nursing Boston College 140 Commonwealth Avenue Chestnut Hill, MA 02467 Phone: (617) 552-6133 Email: burges@bc.edu | VADM Richard Carmona, M.D., M.P.H., FACS U.S. Surgeon General Office of the Surgeon General 5600 Fishers Lane Parklawn Building, Room 18-67 Rockville, MD 20857 Phone: (301) 443-4000
Dana Carr, M.P.H. Program Specialist Office of Safe and Drug-Free Schools U.S. Department of Education 400 Maryland Avenue, SW FB 6 Washington, DC 20202 Phone: (202) 260-3954 Email: dana.carr@ed.gov | David Chadwick, M.D., Ph.D. Professor Department of Pediatrics University of Utah 30 North 1900 East Salt Lake City, Utah 84132 Phone: (801) 588-2360 Email: dlchadwick1@earthlink.net
Mark Chaffin, Ph.D. Professor of Pediatrics University of Oklahoma Health Sciences Center P.O. Box 26901, CSC 225 Oklahoma City, OK 73190 Phone: (405) 271-8858 Email: mark-chaffin@ouhsc.edu | Marc Cherna Director Department of Human Services Allegheny County Department of Human Services 933 Penn Avenue, 5th Floor Pittsburgh, PA 15222-3872 Phone: (412) 350-5701 Email: mcherna@dhs.county.allegheny.pa.us
Cindy Christian, M.D. Co-Director Safe Place: The Center for Child Protection and Health The Children's Hospital of Philadelphia 34th Street and Civic Center Boulevard Philadelphia, PA 19104-4399 Phone: (215) 590-2058 Email: christian@email.chop.edu | Robert Clyman, M.D. American Academy of Child and Adolescent Psychiatry University of Colorado Health Sciences Center 4200 East 9th Avenue Denver, CO 80262 Phone: (303) 864-5255 Email: clyman.rob@tchden.org
Michele Booth Cole, J.D. Executive Director Safe Shores The D.C. Children's Advocacy Center 300 E Street, N.W. Washington, DC 20001 Phone: (202) 638-2575 Email: mboothcole@safeshores.org | Angela Corbin Family and Children's Health Programs Group Center for Medicare & Medicaid Services 7500 Security Boulevard Mailstop S2-01-16 Baltimore, MD 21244 Phone: (410) 786-1285 Email: acorbin@cms.hhs.gov
Theresa Costello Director National Resource Center on Child Protective Services ACTION for Child Protection, Inc. 925 #4 Sixth Street, N.W. Albuquerque, NM 87102 Phone: (505) 345-2444 Email: theresa.costello@actionchildprotection.org | Theresa Covington, M.P.H. Director National MCH Center for Child Death Review 2438 Woodlake Circle, Suite 240 Okemos, MI 48864 Phone: (800) 656-2434 Email: tcovingt@mphi.org
Terry Cross, M.S.W., ACSW, LCSW Executive Director National Indian Child Welfare Association 5100 Southwest Macadam Avenue, Suite 300 Portland, OR 92739 Phone: (503) 222-4044 Email: tlcross@nicwa.org | Stacey D. Cunningham, M.S.W. Senior Program Associate National Black Child Development Institute 1101 15th Street, N.W., Suite 900 Washington, DC 20005 Phone: (202) 833-2220, ext. 129 Email: scunningham@nbcdi.org
Lonna Davis Family Violence Prevention Fund 685 Centre Street Jamaica Plain, MA 02130 Phone: (617) 522-2770 Email: lonna@endabuse.org | Diane DePanfilis, Ph.D. Associate Professor and Co-Director Center for Families University of Maryland 525 West Redwood Street Baltimore, MD 21201 Phone: (410) 706-3609 Email: ddepanfi@ssw.umaryland.edu
Kevin Dinnin Executive Director/CEO Baptist Child and Family Services 909 Northeast Loop 410, Suite 800 San Antonio, TX 78209-1311 Phone: (210) 832-5000 Email: kdinnin@bcfs.net | Howard Dubowitz, M.D., M.S. Co-Director, Center for Families University of Maryland School of Medicine 22 South Greene Street 1 George Gray Hall Baltimore, MD 21201 Phone: (410) 328-8919 Email: hdubowitz@peds.umaryland.edu
John Eckenrode, Ph.D. Family Life Development Center Cornell University 21 Renwick Heights Road Ithaca, NY 14853 Phone: (607) 255-0834 Email: jje1@cornell.edu | Byron Egeland, Ph.D. Irving B. Harris Professor of Child Development University of Minnesota 230 Child Development 51 East River Road Minneapolis, MN 55455-0345 Phone: (612) 624-5273 Email: egela001@umn.edu
Eileen Elias, M.Ed. Deputy Director Office on Disability Office of the Secretary 200 Independence Avenue, S.W., Room 637D Washington, DC 20201 Phone: (202) 205-1104 Email: eileen.elias@hhs.gov | Diana English, Ph.D. Washington State Department of Social and Health Services 101 Israel Road, S.E. Olympia, WA 98504-7890 Phone: (206) 933-3535 Email: endi300@dshs.wa.gov
Anna Falkenstern Health Resources and Services Administration 5600 Fishers Lane Parklawn Building Rockville, MD 20857 Phone: (301) 443-2243 Email: | Sarah Foster, M.P.H. Acting Associate Director for Policy, Planning, and Evaluation National Center for Injury Prevention and Control Centers for Disease Control and Prevention 4770 Buford Highway, N.E., MS K-61 Atlanta, GA 30341 Phone: (770) 488-1316 Email: sjf4@cdc.gov
Reem Ghandour, M.P.A. Office of Women's Health Health Resources and Services Administration 5600 Fishers Lane Parklawn Building, Room 18A-44 Rockville, MD 20857 Phone: (301) 443-3786 Email: rghandour@hrsa.gov | Margaret Giannini, M.D., FAAP Director Office on Disability Office of the Secretary 200 Independence Avenue, S.W., Room 637D Washington, DC 20201 Phone: (202) 205-1016 Email: margaret.giannini@hhs.gov
Maria Gomez, R.N., M.P.H. President/CEO Mary's Center for Maternal and Child Care, Inc. 2333 Ontario Road, N.W. Washington, DC 20009 Phone: (202) 483-8319, ext. 328 Email: info@maryscenter.org | Katherine Gottlieb, M.B.A. President/CEO Southcentral Foundation 4501 Diplomacy Drive Anchorage, AK 99508 Phone: (907) 729-4955 Email: katherineg@scf.scc
Kathi Grasso, J.D. Senior Juvenile Justice Policy and Legal Advisor Office of Juvenile Justice and Delinquency Prevention U.S. Department of Justice 810 7th Street, N.W. Washington, DC 20531 Phone: (202) 616-7567 Email: kathi.grasso@usdoj.gov | Brook McClintic Griese, Ph.D. Research Director Judith Ann Griese Foundation 1600 Downing Street, Suite 200 Denver, CO 80218 Phone: (813) 974-8545 Email: brookmcclintic@hotmail.com
Neil Guterman, Ph.D., M.S.W. School of Social Work Columbia University 1255 Amsterdam Avenue New York, NY 10027 Phone: (212) 851-2385 Email: nbg2@columbia.edu | Neal Halfon, M.D., M.P.H. Professor of Pediatrics, Public Health and Public Policy UCLA Center for Healthier Children, Families and Communities 1100 Glendon, Suite 850 Los Angeles, CA 90024 Phone: (310) 794-0967 Email: nhalfon@ucla.edu
Isadora Hare, M.S.W., LCSW Public Health Analyst Division of Child, Adolescent, and Family Health Health Resources and Services Administration 5600 Fishers Lane Parklawn Building, Room 18A-39 Rockville, MD 20857 Phone: (301) 443-6392 Email: isadore.hare@hhs.hrsa.gov | William Harris, Ph.D. Chair Children's Research and Education Institute 2 Brighton Street Belmont, MA 02478 Phone: (617) 201-7564 Email: kidspac@mindspring.com
Betty Lee Hawks, M.A. Special Assistant to the Director Office of Minority Health Office of Public Health and Science 1101 Wootton Parkway, Suite 600 Rockville, MD 20852 Phone: (301) 443-5084 Email: bhawks@osophs.dhhs.gov | Maxine Hayes, M.D. Washington State Health Officer Washington State Department of Health 101 Israel Road, S.E. Olympia, WA 98504-7890 Phone: (360) 236-4018 Email: maxine.hayes@doh.wa.gov
CAPT Karen Hench, R.N., M.S. Public Health Advisor Health Resources and Services Administration 5600 Fishers Lane Parklawn Building, Room 10C-16 Rockville, MD 20857 Phone: (301) 443-9708 Email: khench@hrsa.gov | Diedra Henry-Spires, M.P.H. Office on Women's Health Office of Public Health and Science U.S. Department of Health and Human Services 200 Independence Avenue, S.W., Room 718-F Washington, DC 20201 Phone: (202) 401-9582 Email: dhenry@osophs.dhhs.gov
Karen Seaver Hill Associate Director for Child Advocacy National Association of Children's Hospitals and Related Institutions 401 Wythe Street Alexandria, VA 22315 Phone: (703) 797-6035 Email: khill@nachri.org | John Holton, Ph.D. President Prevent Child Abuse America 200 South Michigan Avenue, 17th Floor Chicago, IL 60604-2404 Phone: (312) 663-3520 Email: jholton@preventchildabuse.org
Andrew Hsi, M.D., M.P.H. Director Division of General Pediatrics University of New Mexico Health Sciences Center 1 University of New Mexico Albuquerque, NM 87131-5001 Phone: (505) 272-6843 Email: ahsi@salud.unm.edu | Bill Isler President Family Communications, Inc. 4802 Fifth Avenue Pittsburgh, PA 15213 Phone: (412) 687-2990, ext. 222 Email: isler@fci.org
Annette Jacobi, J.D. Director Office of Child Abuse and Neglect Oklahoma State Department of Health 2500 North Lincoln Boulevard Oklahoma City, OK 73105-4599 Phone: (405) 271-9444 Email: annettej@health.ok.gov | Calvin Johnson, M.D., M.P.H. Secretary of Health Commonwealth of Pennsylvania 7th and Forster Streets Harrisburg, PA 17120 Phone: (717) 787-6436 Email: calvjohnso@state.pa.us
Robert L. Johnson, M.D. Professor of Pediatrics and Psychiatry University of Medicine and Dentistry of New Jersey Medical Science Building, Room F-540 185 South Orange Avenue Newark, NJ 07101-1709 Phone: (973) 972-5277 Email: rjohnson@umdnj.edu | Barbara Jones, M.S.W., MSPH DHHS Emerging Leader Office of Disease Prevention and Health Promotion U.S. Department of Health and Human Services 1101 Wootton Parkway, Suite LL100 Rockville, MD 20852 Phone: (240) 453-8271 Email: bjones2@osophs.dhhs.gov
Wanda Jones, DrPH Deputy Assistant Secretary for Health Office on Women's Health U.S. Department of Health and Human Services 200 Independence Avenue, S.W., Room 712-E Washington, DC 20201 Phone: (202) 690-7650 Email: wjones@osophs.dhhs.gov | RADM Woodie Kessel, M.D., M.P.H. Assistant Surgeon General Deputy Director for Medicine and Science Office of Disease Prevention and Health Promotion 1101 Wootton Parkway, Suite LL100 Rockville, MD 20852 Phone: (240) 453-8280 Email: wkessel@osophs.dhhs.gov
Gillian Kimura, M.P.H. Office on Women's Health U.S. Department of Health and Human Services 200 Independence Avenue, S.W. Washington, DC 20201 Phone: (202) 401-1170 Email: ghkimura@osophs.dhhs.gov | Gary Knell, J.D. President/CEO Sesame Workshop One Lincoln Plaza New York, NY 10023 Phone: (212) 875-6876 Email: gary.knell@sesameworkshop.org
David Kolko, Ph.D. Professor of Psychiatry University of Pittsburgh Medical Center 541 Bellefield Towers Pittsburgh, PA 15213 Phone: (412) 624-2096 Email: kolkodj@msx.upmc.edu | Charles LaVallee Vice President Highmark Caring Foundation Pittsburgh Center for Grieving Children 620 Stanwix Street Pittsburgh, PA 15222 Phone: (412) 544-1689 Email: charles.lavallee@highmark.com
Cindy Lederman, J.D. Presiding Judge Miami-Dade Juvenile Court 3300 N.W. 27th Avenue, Room 201 Miami, FL 33142 Phone: (305) 638-6087 Email: clederman@jud11.flcourts.org | Dawn Levinson, M.S.W. Policy Advisor on Children and Families Office of Policy, Planning, and Budget Office of the Administrator Substance Abuse and Mental Health Services Administration 1 Choke Cherry Road, Room 8-1062 Rockville, MD 20857 Phone: (240) 276-2015 Email: dawn.levinson@samhsa.hhs.gov
George Lithco, J.D. The Skipper Initiative Jacobowitz & Gubits, LLP 158 Orange Avenue P.O. Box 367 Walden, NY 12586 Phone: (845) 778-2121, ext. 272 Email: gwl@jacobowitz.com | John Lutzker, Ph.D. Chief, Prevention Development and Evaluation Branch Division of Violence Prevention National Center for Injury Prevention and Control Centers for Disease Control and Prevention 4770 Buford Highway, N.E., MS K-60 Atlanta, GA 30333 Phone: (770) 488-1557 Email: jlutzker@cdc.gov
Yvonne T. Maddox, Ph.D. Deputy Director National Institute of Child Health and Human Development National Institutes of Health 1 Center Drive Bethesda, MD 20892 Phone: (301) 496-1848 Email: ym16x@nih.gov | Valerie Maholmes, Ph.D. Program Officer Child Development and Behavior Branch National Institute of Child Health and Human Development National Institutes of Health Room 4B05E, MSC 7510 6100 Executive Boulevard Bethesda, MD 20892 Phone: (301) 496-1514 Email: maholmev@mail.nih.gov
Dorothy Marge, Ph.D. Research Assistant Professor Department of Physical Medicine and Rehabilitation State University of New York Upstate Medical University 449 Old Orchard Circle Millersville, MD 21108 Phone: (410) 729-9566 Email: dorothy.marge@comcast.net | Michael Marge, Ed.D. Special Assistant Office on Disability Office of the Secretary U.S. Department of Health and Human Services 200 Independence Avenue, S.W., Room 637D Washington, DC 20201 Phone: 202-401-5844 Email: michael.marge@HHS.GOV
Sue Martone, M.P.A. Assistant Deputy Director Office of Behavioral Health Allegheny County Department of Human Services 304 Wood Street Pittsburgh, PA 15222 Phone: (412) 350-7399 Email: smartone@dhs.county.allegheny.pa.us | Elizabeth McCord, M.D. Department of Family Medicine East Tennessee State University Box 70621 Johnson City, TN 37614 Phone: (423) 915-0117 Email: mailto:mccord@mail.etsu.edu
RADM Kenneth Moritsugu, M.D., M.P.H. U.S. Deputy Surgeon General Office of the Surgeon General 5600 Fishers Lane Parklawn Building, Room 18-67 Phone: (301) 443-4000 | Susan Moskosky, M.S., R.N.C. Director Office of Family Planning Office of Population Affairs 1101 Wootton Parkway, Suite 700 Rockville, MD 20852 Phone: (301) 594-4004 Email: smoskosky@osophs.dhhs.gov
Charlotte Mullican, M.P.H. Senior Advisor for Mental Health Research Center for Primary Care, Prevention, and Clinical Partnerships Agency for Healthcare Research and Quality 540 Gaither Road, Suite 6129 Rockville, MD 20850 Phone: (301) 427-1495 Email: mailto:cmullica@ahrq.gov | Johanna Nestor, M.P.H. Public Health Analyst Office of Adolescent Pregnancy Programs Office of Population Affairs 1101 Wootton Parkway, Suite 700 Rockville, MD 20852 Phone: (301) 594-4004 Email: jnestor@osophs.dhhs.gov
Bunny Nicholson, M.S.W. President Nicholson and Associates 2368 South Fillmore Street Denver, CO 80210 Phone: (303) 758-0799 Email: nicholsonspencer@msn.com | Catherine Nolan, M.S.W., ACSW Director Children's Bureau Office on Child Abuse and Neglect Administration for Children and Families 330 C Street, S.W. Washington, DC 20447 Phone: (202) 260-5140 Email: cnolan@acf.hhs.gov
Emmeline Ochiai, J.D., M.P.H. Office of Disease Prevention and Health Promotion 1101 Wootton Parkway, Suite LL100 Rockville, MD 20852 Phone: (240) 453-8259 Email: eochiai@osophs.dhhs.gov | David Olds, Ph.D. Director Kempe Prevention Research Center for Family and Child Health University of Colorado Health Sciences Center 4200 East Ninth Avenue Denver, CO 80262 Phone: (303) 864-5205 Email: olds.david@tchden.org
Susan Orr, Ph.D. Associate Commissioner Children's Bureau Office on Child Abuse and Neglect Administration for Children and Families 330 C Street, S.W. Switzer Building, Room 2318 Washington, DC 20447 Phone: (202) 205-8618 Email: dorr@acf.hhs.gov | Joy Osofsky, Ph.D. President ZERO TO THREE 2000 M Street, N.W., Suite 200 Washington, DC 20036 Phone: (202) 638-1144 Email: josofs@lsuhsc.edu
Elaine Parry, M.S. Immediate Office of the Administrator Substance Abuse and Mental Health Services Administration 1 Choke Cherry Road, Room 7-1111 Rockville, MD 20857 Phone: (240) 276-2018 Email: elaine.parry@samhsa.hhs.gov | Marilyn Peterson, M.S.W. Director CAARE Diagnostic and Treatment Center University of California Davis Children's Hospital 3300 Stockton Boulevard Sacramento, CA 95820 Phone: (916) 734-7615 Email: marilyn.peterson@ucdmc.ucdavis.edu
Molly Petersen, M.S.W., M.P.P. Child Welfare Policy Analyst Administration for Children and Families 901 D Street, S.W. ashington, DC 20447 Phone: (202) 401-4733 Email: mpeterson@acf.hhs.gov | Michele Pierce Principal Harriet Tubman Charter School 3565 Third Avenue Bronx, NY 10456 Phone: (718) 537-9912 Email: mipierce@verizon.net
Cici Porter Director Journey to Wholeness Project 1726 South Clementine Street Oceanside, CA 92054 Phone: (760) 433-6536 Email: cicipg@cox.net | Terracita A. Powell Psychologist National Institute of Mental Health National Institutes of Health 3317 Sir Thomas Drive Silver Spring, MD 20914 Phone: (301) 402-4798 Email: terracitapowell@mail.nih.gov
Deborah Price Deputy Undersecretary Office of Safe and Drug-Free Schools U.S. Department of Education 400 Maryland Avenue, SW FB 6 Washington, DC 20202 Phone: (202) 205-4169 Email: deborah.price@ed.gov | Ronald Prinz, Ph.D. Department of Psychology University of South Carolina Columbia, SC 29208 Phone: (803) 777-7143 Email: prinz@sc.edu
Sharon Ramey, Ph.D. Director Georgetown Center on Health and Education Georgetown University 3700 Reservoir Road, N.W. Box 571107 Washington, DC 20057-1017 Phone: (202) 687-1389 Email: sr222@georgetown.edu | Lauren Raskin Ramos, M.P.H. Senior Director Maternal and Child Health Policy Association of State and Territorial Health Officials 1275 K Street, N.W., Suite 800 Washington, DC 20005-4006 Phone: (202) 371-9090, ext. 1622 Email: lraskin@astho.org
Bettina Richardson Bexar County District Attorney's Office Family Justice Center 300 Dolorosa, 5th Floor San Antonio, TX 78205-3030 Phone: (210) 335-2954 Email: brichardson@co.bexar.tx.us | Lydia Rochfort Program Director Indian Child Social Services Southern Indian Health Council 4058 Williams Road Alpine, CA 91903-2128 Phone: (619) 445-1188 Email: lrochfort@sihc.org
CAPT Penelope Royall, P.T., M.S.W. Deputy Assistant Secretary for Health Office of Disease Prevention and Health Promotion 1101 Wootton Parkway, Suite LL100 Rockville, MD 20852 Phone: (240) 453-8280 Email: proyall@osophs.dhhs.gov | Susan Royer Sesame Workshop One Lincoln Plaza New York, NY 10023 Phone: (212) 875-6876 Email: susan.royer@sesameWorkshop.org
Desmond Runyan, M.D., DrPH Professor and Chair of Social Medicine The University of North Carolina CB #7240 Chapel Hill, NC 27599 Phone: (919) 843-8261 Email: drunyan@unc.edu | Marilyn Sandberg-Barr Founder and Executive Director National Center on Shaken Baby Syndrome 2955 Harrison Boulevard, Suite 102 Ogden, UT 84403 Phone: (801) 627-3399 Email: mail@dontshake.com
Ben Saunders, M.D. Director National Crime Victims Research and Treatment Center Medical University of South Carolina 165 Cannon Street Charleston, SC 29425 Phone: (843) 792-2945 Email: saunders@musc.edu | Katherine Darke Schmitt, M.P.P. Social Policy Analyst Office of Juvenile Justice and Delinquency Prevention Office of Justice Program U.S. Department of Justice 810 7th Street, N.W. Washington, DC 20202 Phone: (202) 616-7373 Email: katherine.darke.schmitt@usdoj.gov
Edward Schor, M.D. Vice President The Commonwealth Fund 1 East 75th Street New York, NY 10021 Phone: (212) 606-3800 Email: els@cmwf.org | Patrick Sheeran, D.P.A. Director Office of Adolescent Pregnancy Programs Office of Population Affairs 1101 Wootton Parkway, Suite 700 Rockville, MD 20852 Phone: (301) 594-4004 Email: psheeran@osophs.dhhs.gov
Nancy Siegel, M.S.W. Consultant NBS Associates 10141 Cape Ann Drive Columbia, MD 21046 Phone: (410) 730-2278 Email: nbs979@comcast.net | Jerry Silverman, M.S.W. Assistant Secretary for Planning and Evaluation U.S. Department of Health and Human Services 200 Independence Avenue, S.W. Washington, DC 21202 Phone: (202) 690-5654 Email: jerry.silverman@hhs.gov
Maxine Stein President/CEO Stop It Now! 351 Pleasant Street, Suite B319 Northampton, MA 01060 Phone: (413) 587-3500 Email: mstein@stopitnow.org | Patricia Sullivan, Ph.D. Director Center for Abused Children with Disabilities Creighton University School of Medicine 2400 California Place Omaha, NE 68131 Phone: (402) 498-1656 Email: tsullivan@creighton.edu
Susan Swedo, M.D. Associate Director for Child and Adolescent Research and Director, Division of Pediatric Translational Research and Treatment National Institute of Mental Health National Institutes of Health 6001 Executive Boulevard Room 6196, MSC 9617 Rockville, MD 20852 Phone: (301) 443-5944 Email: swedos@mail.nih.gov | CAPT Judith Thierry, D.O. Director, Maternal Child Health Indian Health Service 12300 Twinbrook Parkway Twinbrook Metro Plaza, Suite 450 Rockville, MD 20852 Phone: (301) 443-5070 Email: jthierry@na.ihs.gov
Clarice Walker Board President, Safe Shores The DC Children's Advocacy Center 300 E Street, N.W. Washington, DC 20001 Phone: (202) 638-2575 Email: claricedwalker@aol.com | Ellen Wartella, Ph.D. Executive Vice President and Provost University of California - Riverside 900 University Avenue Riverside, CA 92521 Phone: (951) 827-5034 Email: wartella@admin.ucr.edu
Ramona Williams Social Work Consultant Indian Health Service 12300 Twinbrook Parkway Twinbrook Metro Place, Suite 605 Rockville, MD 20852 Phone: (301) 443-1539 Email: ramona.williams@ns.ihs.gov | RADM Robert Williams, P.E., D.E.E. Chief of Staff Office of the Surgeon General 5600 Fishers Lane Parklawn Building, Room 18067 Rockville, MD 20857 Phone: (301) 443-4000
Charles Wilson, M.S.W. San Diego Children's Hospital and Center 3020 Children's Way San Diego, CA 92123 Phone: (858) 966-5911 Email: cwilson@chsd.org | Brian Wyant Director Division of Health Risk Reduction Pennsylvania Department of Health 7th and Forster Streets Harrisburg, PA 17120 Phone: (717) 787-5900 Email: bwyant@state.pa.us
Joan Yengo Vice President Mary's Center for Maternal and Child Care, Inc. 2333 Ontario Road, N.W. Washington, DC 20009 Phone: 202-483-8319, ext. 321 Email: jyengo@maryscenter.org