# Surgeon General's Workshop Agenda

Wednesday, March 30, 2005
8:30 a.m. | Introduction and Welcome RADM Woodie Kessel, M.D., M.P.H., Assistant Surgeon General VADM Richard Carmona, M.D., M.P.H., FACS, U.S. Surgeon General
8:45 a.m. | Child Maltreatment in America Cristina Beato, M.D., FAAFP, Acting Assistant Secretary for Health Wade Horn, Ph.D., Assistant Secretary for Children and Families RADM Kenneth Moritsugu, M.D., M.P.H., Deputy Surgeon General Susan Orr, Ph.D., Associate Commissioner, Children's Bureau
9:00 a.m. | Family and Survivor Perspectives Cici Porter, Singer/Songwriter/Survivor George Lithco, J.D., Parent and Founder of the Skipper Initiative
9:30 a.m. | Fitness Break
DEFINING THE PUBLIC HEALTH APPROACH TO PREVENTING CHILD MALTREATMENT: KEY ELEMENTS
9:45 a.m. | Child Health and Development, and Public Health Systems Integration Moderator: Carol Berkowitz, M.D., President, American Academy of Pediatrics Expositeurs: Neal Halfon, M.D., M.P.H., Professor, University of California at Los Angeles Sharon Ramey, Ph.D., Professor, Georgetown University Maria Gomez, R.N., M.P.H., Director, Mary's Center for Maternal and Child Care
10:15 a.m. | Discussion
11:15 a.m. | Parent, Family, Community, and Society: Influences Shaping Development Moderator: Cindy Christian, M.D., Professor, Children's Hospital of Philadelphia Expositeurs: David Olds, Ph.D., Professor, Kempe Prevention Research Center, University of Colorado Dorothy Marge, Ph.D., Assistant Professor, SUNY Upstate Medical University Stacey Cunningham, M.S.W., National Black Child Development Institute
12:30 p.m. | Lunch
2:00 p.m. | Formative and Operational Systems Change Moderator: Gary Knell, J.D., President, Sesame Workshop Expositeurs: Marc Cherna, Director, Department of Human Services Allegheny County Michele Booth Cole, J.D., Executive Director, Safe Shores
2:30 p.m. | Discussion
3:30 p.m. | Fitness Break
3:45 p.m. | Summary of Key Elements of the Public Health Approach Catherine Nolan, M.S.W., ACSW, Director, Office on Child Abuse and Neglect Charles Wilson, M.S.W., Executive Director, Chadwick Center for Children and Families, San Diego Children's Hospital and Health Center
4:15 p.m. | Day Two Preview Assistant Surgeon General Kessel
Thursday, March 31, 2005
8:30 a.m. | Review of Day One – Introduction to Day Two Assistant Surgeon General Kessel
KEY ELEMENTS FOR ACHIEVING THE PUBLIC HEALTH APPROACH TO PREVENTING CHILD MALTREATMENT
8:45 a.m. | Parent and Family Innovations and Opportunities for Prevention Moderator: Katherine Gottlieb, M.B.A., President/CEO, Southcentral Foundation Expositeurs: Cindy Lederman, J.D., Presiding Judge, Miami-Dade County Juvenile Court Terry Cross, M.S.W., ACSW, LCSW, Executive Director, National Indian Child Welfare Association Rob Clyman, M.D., American Academy of Child and Adolescent Psychiatry
9:15 a.m. | Discussion
10:15 a.m. | Fitness Break
10:30 a.m. | Community and Society Innovations and Opportunities for Prevention Moderator: Jim Bueermann, M.B.A., Chief of Police, Redlands California Expositeurs: Maxine Hayes, M.D., Washington State Health Officer Michelle Pierce, Principal, Harriet Tubman Charter School Bill Isler, President, Family Communications
11:00 a.m. | Discussion
12:00 p.m. | Lunch
1:30 p.m. | Critical Thinking for a New National Public Health Priority Moderator: Kevin Dinnin, CEO, Baptist Child and Family Services Expositeurs: Ed Schor, M.D., Vice President, The Commonwealth Fund Calvin Johnson, M.D., M.P.H., Secretary of Health, Commonwealth of Pennsylvania Ellen Wartella, Ph.D., Executive Vice Chancellor/Provost, University of California-Riverside
2:00 p.m. | Discussion
3:00 p.m. | Fitness Break
3:15 p.m. | Summary of Key Steps for Achieving the Public Health Approach Shay Bilchik, J.D., President/CEO, Child Welfare League of America
3:45 p.m. | Preventing Child Maltreatment and Promoting Child Well Treatment U.S. Surgeon General Carmona
4:00 p.m. | Closing Assistant Surgeon General Kessel