# References

Eckenrode J, Ganzel B, Henderson CR, Smith E, Olds DL, Powers J, Cole R, Kitzman H, Sidora K. Preventing child abuse and neglect with a program of nurse home visitation: the limiting effects of domestic violence. JAMA. 2000;284(11):1385-91. [pmid: 10989400].
Eckenrode J, Zielinski D, Smith E, Marcynyszyn LA, Henderson CR, Kitzman H, Cole R, Powers J, Olds DL. Child maltreatment and the early onset of problem behaviors: can a program of nurse home visitation break the link?. Dev Psychopathol. 2001;13(4):873-90. [pmid: 11771912].
Fiscella K, Kitzman HJ, Cole RE, Sidora KJ, Olds D. Does child abuse predict adolescent pregnancy?. Pediatrics. 1998;101(4 Pt 1):620-4. [pmid: 9521944].
Lane WG, Rubin DM, Monteith R, Christian CW. Racial differences in the evaluation of pediatric fractures for child abuse. JAMA. 2002;288:1603-09. [pmid: 12350191].
National Research Council, Institute of Medicine (JP Shonkoff and D Phillips (Eds)): From Neurons to Neighborhoods. Washington, DC: National Academy Press, 2000.
Olds DL, Eckenrode J, Henderson CR, Kitzman H, Powers J, Cole R, Sidora K, Morris P, Pettitt LM, Luckey D. Long-term effects of home visitation on maternal life course and child abuse and neglect. Fifteen-year follow-up of a randomized trial. JAMA. 1997;278(8):637-43. [pmid: 9272895].
Olds DL, Henderson CR, Chamberlin R, Tatelbaum R. Preventing child abuse and neglect: a randomized trial of nurse home visitation. Pediatrics. 1986;78(1):65-78. [pmid: 2425334].
Olds DL, Henderson CR, Kitzman HJ, Cole RE. Effects of prenatal and infancy nurse home visitation on surveillance of child maltreatment. Pediatrics. 1995;95(3):365-72. [pmid: 7862474].