# Prologue

"I can think of no terror that could be more devastating than child maltreatment, violence, abuse, and neglect perpetrated by one human being upon another...I believe it is time for critical thinking to formulate a new national public health priority, preventing child maltreatment and promoting child well treatment."

(Surgeon General Richard H. Carmona, M.D., M.P.H.)

The 2005 Surgeon General's Workshop on Making Prevention of Child Maltreatment a National Priority: Implementing Innovations of a Public Health Approach was convened to discover and elucidate effective strategies for preventing child maltreatment and promoting child well treatment by:

- Advancing prevention and promotion as a national public health priority
- Enhancing evidence-based prevention and promotion strategies
- Integrating prevention and promotion services into all systems of care
- Incorporating child development literacy into the national consciousness
- Strengthening essential public-private care systems
- Establishing a strategic public health approach for prevention and promotion.

The 2005 Surgeon General's Workshop on Making Prevention of Child Maltreatment a National Priority: Implementing Innovations of a Public Health Approach was uniquely structured to enable and encourage active exchange of ideas and debate among caring and committed colleagues from diverse backgrounds. Participants included representatives from the fields of medicine, public health, child development, childhood disabilities, social services, child welfare, education, law enforcement, juvenile justice, communications, and mental health. A wide range of valued perspectives from academia, foundations, advocacy groups, professional organizations, the faith-based community, and all levels of government were elicited.

The 2005 Surgeon General's Workshop on Making Prevention of Child Maltreatment a National Priority: Implementing Innovations of a Public Health Approach was a part of the Surgeon General's 2005 Year of the Healthy Child Agenda examining issues surrounding the health and well being of children focusing efforts on the body, mind and spirit of the growing children throughout the Nation and the world.

In responding to the question - what is child maltreatment? Surgeon General Carmona replied, "It is unacceptable and it is preventable!"