# References

1 Islami F, Marlow EC, Thomson B, . Proportion and number of cancer cases and deaths attributable to potentially modifiable risk factors in the United States, 2019. CA Cancer J Clin. Jul 11 2024; doi:10.3322/caac.21858
2 Esser MB, Sherk A, Liu Y, Henley SJ, Naimi TS. Reducing Alcohol Use to Prevent Cancer Deaths: Estimated Effects Among U.S. Adults. Am J Prev Med. 2024 Apr;66(4):725–729. doi: 10.1016/j.amepre.2023.12.003. PMID: 38514233; PMCID: PMC10963036.38514233
3 “Updated US Drinking Norms (2020 Data).” Alcohol Research Group, https://arg.org/news/updated-us-drinking-norms-2020-data/. Accessed 8 November 2024.
4 “2019 AICR Cancer Risk Awareness Survey.” American Institute for Cancer Research, https://www.aicr.org/wp-content/uploads/2020/02/2019-Survey.pdf. Accessed 24 August 2024.
5 IARC Working Group on the Evaluation of Carcinogenic Risks to Humans., International Agency for Research on Cancer., National Cancer Institute (U.S.). Alcohol drinking. IARC monographs on the evaluation of carcinogenic risks to humans,. World Health Organization, International Agency for Research on Cancer; 1988:416 p.
6 WCRF/AICR. World Cancer Research Fund/American Institute for Cancer Research. Diet, nutrition, physical activity and cancer: a global perspective. Continuous Update Project Expert Report. 2018.
7 Personal Habits and Indoor Combustions: IARC Monographs on the Evaluation of Carcinogenic Risks to Humans Volume 100E. IARC. 2012 https://publications.iarc.fr/122
8 Jung S, Wang M, Anderson K, Baglietto L, Bergkvist L, Bernstein L, van den Brandt PA, Brinton L, Buring JE, Eliassen AH, Falk R, Gapstur SM, Giles GG, Goodman G, Hoffman-Bolton J, Horn-Ross PL, Inoue M, Kolonel LN, Krogh V, Lof M, Maas P, Miller AB, Neuhouser ML, Park Y, Robien K, Rohan TE, Scarmo S, Schouten LJ, Sieri S, Stevens VL, Tsugane S, Visvanathan K, Wilkens LR, Wolk A, Weiderpass E, Willett WC, Zeleniuch-Jacquotte A, Zhang SM, Zhang X, Ziegler RG, Smith-Warner SA. Alcohol consumption and breast cancer risk by estrogen receptor status: in a pooled analysis of 20 studies. Int J Epidemiol. 2016 Jun;45(3):916–28. doi: 10.1093/ije/dyv156. Epub 2015 Aug 28. PMID: 26320033; PMCID: PMC5005939.26320033
9 Di Credico G, Polesel J, Dal Maso L, Pauli F, Torelli N, Luce D, Radoï L, Matsuo K, Serraino D, Brennan P, Holcatova I, Ahrens W, Lagiou P, Canova C, Richiardi L, Healy CM, Kjaerheim K, Conway DI, Macfarlane GJ, Thomson P, Agudo A, Znaor A, Franceschi S, Herrero R, Toporcov TN, Moyses RA, Muscat J, Negri E, Vilensky M, Fernandez L, Curado MP, Menezes A, Daudt AW, Koifman R, Wunsch-Filho V, Olshan AF, Zevallos JP, Sturgis EM, Li G, Levi F, Zhang ZF, Morgenstern H, Smith E, Lazarus P, La Vecchia C, Garavello W, Chen C, Schwartz SM, Zheng T, Vaughan TL, Kelsey K, McClean M, Benhamou S, Hayes RB, Purdue MP, Gillison M, Schantz S, Yu GP, Chuang SC, Boffetta P, Hashibe M, Yuan-Chin AL, Edefonti V. Alcohol drinking and head and neck cancer risk: the joint effect of intensity and duration. Br J Cancer. 2020 Oct;123(9):1456–1463. doi: 10.1038/s41416-020-01031-z. Epub 2020 Aug 24. PMID: 32830199; PMCID: PMC7592048.32830199
10 Bagnardi V, Rota M, Botteri E, . Alcohol consumption and site-specific cancer risk: a comprehensive dose-response meta-analysis. Br J Cancer. Feb 3 2015;112(3):580–93. doi:10.1038/bjc.2014.579 25422909
11 GBD. Alcohol use and burden for 195 countries and territories, 1990-2016: a systematic analysis for the Global Burden of Disease Study 2016. Lancet. Sep 22 2018;392(10152):1015–1035. doi:10.1016/s0140-6736(18)31310-2 30146330
12 Rumgay, H., Shield, K., Charvat, H., Ferrari, P., Sornpaisarn, B., Obot, I., Islami, F., Lemmens, V. E. P. P., Rehm, J., & Soerjomataram, I. (2021). Global burden of cancer in 2020 attributable to alcohol consumption: a population-based study. The Lancet. Oncology, 22(8), 1071–1080. 10.1016/S1470-2045(21)00279-5 34270924
13 National Center for Statistics and Analysis. (2024, August, Revised). Alcohol-impaired driving: 2022 data (Traffic Safety Facts. Report No. DOT HS 813 578). National Highway Traffic Safety Administration.
14 “Alcohol-Related Disease Impact (ARDI) Application.” Centers for Disease Control and Prevention, https://nccd.cdc.gov/DPH_ARDI. Accessed 24 August 2024.
15 U.S. Department of Agriculture and U.S. Department of Health and Human Services. Dietary Guidelines for Americans, 2020–2025. 9th Edition. December 2020.
16 HILL AB. THE ENVIRONMENT AND DISEASE: ASSOCIATION OR CAUSATION? Proc R Soc Med. 1965 May;58(5):295–300. PMID: 14283879; PMCID: PMC1898525.14283879
17 U.S. Surgeon General’s Advisory Committee on Smoking and Health. Smoking and Health: Report of the Advisory Committee to the Surgeon General of the Public Health Service Washington, D.C: U.S. Department of Health, Education and Welfare, Public Health Service; 1964.
18 Office of the Surgeon General (US); Office on Smoking and Health (US). The Health Consequences of Smoking: A Report of the Surgeon General. Atlanta (GA): Centers for Disease Control and Prevention (US); 2004. PMID: 2066951220669512.
19 Shimonovich M, Pearce A, Thomson H, Keyes K, Katikireddi SV. Assessing causality in epidemiology: revisiting Bradford Hill to incorporate developments in causal thinking. Eur J Epidemiol. 2021 Sep;36(9):873–887. doi: 10.1007/s10654-020-00703-7. Epub 2020 Dec 16. PMID: 33324996; PMCID: PMC8206235.33324996
20 Kenneth J. Rothman and Sander Greenland, 2005: Causation and Causal Inference in Epidemiology. American Journal of Public Health 95, S144_S150, 10.2105/AJPH.2004.059204 16030331
21 Mervyn Susser, What is a Cause and How Do We Know One? A Grammar for Pragmatic Epidemiology, American Journal of Epidemiology, Volume 133, Issue 7, 1 April 1991, Pages 635–648, 10.1093/oxfordjournals.aje.a115939 2018019
22 NTP (National Toxicology Program). 2021. Report on Carcinogens, Fifteenth Edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service. DOI: 10.22427/NTP-OTHER-1003
23 Brooks PJ, Theruvathu JA. DNA adducts from acetaldehyde: Implications for alcohol-related carcinogenesis. Alcohol. 2005;35:187–193. doi: 10.1016/j.alcohol.2005.03.009.16054980
24 Seitz HK, Stickel F. Molecular mechanisms of alcohol-mediated carcinogenesis. Nat Rev Cancer. 2007;7:599–612. doi: 10.1038/nrc2191.17646865
25 Lachenmeier DW, Monakhova YB. Short-term salivary acetaldehyde increase due to direct exposure to alcoholic beverages as an additional cancer risk factor beyond ethanol metabolism. J Exp Clin Cancer Res. 2011 Jan 6;30(1):3. doi: 10.1186/1756-9966-30-3. PMID: 21211027; PMCID: PMC3022748.21211027
26 Stornetta A, Guidolin V, Balbo S. Alcohol-Derived Acetaldehyde Exposure in the Oral Cavity. Cancers. 2018; 10(1):20. 10.3390/cancers10010020 29342885
27 Nieminen MT, Salaspuro M. Local Acetaldehyde—An Essential Role in Alcohol-Related Upper Gastrointestinal Tract Carcinogenesis. Cancers. 2018; 10(1):11. 10.3390/cancers10010011 29303995
28 National Center for Chronic Disease Prevention and Health Promotion. “Alcohol and Cancer.” U.S. Centers for Disease Control and Prevention, https://www.cdc.gov/cancer/risk-factors/alcohol.html#print. Accessed 19 November 2024.
29 IARC Working Group on the Evaluation of Carcinogenic Risks to Humans. Personal habits and indoor combustions. IARC Monogr Eval Carcinog Risks Hum. 2012;100(Pt E):1–538. PMID: 23193840; PMCID: PMC4781577.23193840
30 “Alcohol and Cancer Risk.” National Cancer Institute, https://www.cancer.gov/about-cancer/causes-prevention/risk/alcohol/alcohol-fact-sheet. Accessed 24 August 2024.
31 SG. Facing Addiction in America: The Surgeon General’s Report on Alcohol, Drugs, and Health. 2016.
32 World Cancer Research Fund/American Institute for Cancer Research. Continuous Update Project Expert Report 2018. Diet, nutrition, physical activity and pancreatic cancer. Available at dietandcancerreport.org
33 World Cancer Research Fund International: Continuous Update Project. How Diet, Nutrition and Physical Activity Affect Skin Cancer Risk: Report; 2018. https://www.wcrf.org/wp-content/uploads/2024/10/skin-cancer.pdf Accessed 24 August 2024.
34 Gapstur SM, Bandera EV, Jernigan DH, LoConte NK, Southwell BG, Vasiliou V, Brewster AM, Naimi TS, Scherr CL, Shield KD. Alcohol and Cancer: Existing Knowledge and Evidence Gaps across the Cancer Continuum. Cancer Epidemiol Biomarkers Prev. 2022 Jan;31(1):5–10. doi: 10.1158/1055-9965.EPI-21-0934. Epub 2021 Nov 2. PMID: 34728469; PMCID: PMC8755600.34728469
35 Freudenheim JL. Alcohol’s Effects on Breast Cancer in Women. Alcohol Res. 2020;40(2):11. doi:10.35946/arcr.v40.2.11 32582503
36 Rumgay H, Murphy N, Ferrari P, Soerjomataram I. Alcohol and Cancer: Epidemiology and Biological Mechanisms. Nutrients. Sep 11 2021;13(9) doi:10.3390/nu13093173
37 Hashibe M, Brennan P, Chuang SC, . Interaction between tobacco and alcohol use and the risk of head and neck cancer: pooled analysis in the International Head and Neck Cancer Epidemiology Consortium. Cancer Epidemiol Biomarkers Prev. Feb 2009;18(2):541–50. doi:10.1158/1055-9965.Epi-08-0347 19190158
38 Tóth ME, Vígh L, Sántha M. Alcohol stress, membranes, and chaperones. Cell Stress Chaperones. 2014 May;19(3):299–309. doi: 10.1007/s12192-013-0472-5. PMID: 24122554; PMCID: PMC3982023.24122554
39 Marlies Noordzij, Merel van Diepen, Fergus C. Caskey, Kitty J. Jager, Relative risk versus absolute risk: one cannot be interpreted without the other, Nephrology Dialysis Transplantation, Volume 32, Issue suppl_2, April 2017, Pages ii13–ii18, 10.1093/ndt/gfw465
40 “Odds of Dying.” National Safety Council, https://injuryfacts.nsc.org/all-injuries/preventable-death-overview/odds-of-dying/. Accessed 24 August 2024.
41 Sarich, P., Canfell, K., Egger, S., Banks, E., Joshy, G., Grogan, P., & Weber, M. F. (2021). Alcohol consumption, drinking patterns and cancer incidence in an Australian cohort of 226,162 participants aged 45 years and over. British journal of cancer, 124(2), 513–523. 10.1038/s41416-020-01101-2 33041337
42 “Alcohol’s Effects on Health.” National Institute on Alcohol Abuse and Alcoholism, https://www.niaaa.nih.gov/alcohols-effects-health/alcohol-topics/alcohol-facts-and-statistics/alcohol-use-united-states-age-groups-and-demographic-characteristics. Accessed 24 August 2024.
43 “Cancer Stat Facts: Common Cancer Sites.” National Cancer Institute, https://seer.cancer.gov/statfacts/html/common.html. Accessed 24 August 2024.
44 Gapstur SM, Bouvard V, Nethan ST, . The IARC Perspective on Alcohol Reduction or Cessation and Cancer Risk. N Engl J Med. Dec 28 2023;389(26):2486–2494. doi:10.1056/NEJMsr2306723 38157507
45 Reduction or Cessation of Alcoholic Beverage Consumption. IARC Handbooks of Cancer Prevention Volume 20A https://publications.iarc.fr/Book-And-Report-Series/Iarc-Handbooks-Of-Cancer-Prevention/Reduction-Or-Cessation-Of-Alcoholic-Beverage-Consumption-2024
46 Sim W, Pan JT, Chua CWX, Fong KY, Wong SH, Lee B, Oon HH. Association between alcohol flushing syndrome and cancer: A systematic review and meta-analysis. Ann Acad Med Singap. 2024 Jul 30;53(7):420–434. doi: 10.47102/annals-acadmedsg.2023351. PMID: 39132959.39132959
47 Brooks PJ, Enoch MA, Goldman D, Li TK, Yokoyama A. The alcohol flushing response: an unrecognized risk factor for esophageal cancer from alcohol consumption. PLoS Med. 2009 Mar 24;6(3):e50. doi: 10.1371/journal.pmed.1000050. PMID: 19320537; PMCID: PMC2659709.19320537
48 Im PK, Yang L, Kartsonaki C, Chen Y, Guo Y, Du H, Lin K, Kerosi R, Hacker A, Liu J, Yu C, Lv J, Walters RG, Li L, Chen Z, Millwood IY; China Kadoorie Biobank (CKB) Collaborative Group. Alcohol metabolism genes and risks of site-specific cancers in Chinese adults: An 11-year prospective study. Int J Cancer. 2022 May 15;150(10):1627–1639. doi: 10.1002/ijc.33917. Epub 2022 Jan 20. PMID: 35048370; PMCID: PMC7612513.35048370
49 Karlsson Linnér R, Biroli P, Kong E, Meddens SFW, Wedow R, Fontana MA, Lebreton M, Tino SP, Abdellaoui A, Hammerschlag AR, Nivard MG, Okbay A, Rietveld CA, Timshel PN, Trzaskowski M, Vlaming R, Zünd CL, Bao Y, Buzdugan L, Caplin AH, Chen CY, Eibich P, Fontanillas P, Gonzalez JR, Joshi PK, Karhunen V, Kleinman A, Levin RZ, Lill CM, Meddens GA, Muntané G, Sanchez-Roige S, Rooij FJV, Taskesen E, Wu Y, Zhang F; 23and Me Research Team; eQTLgen Consortium; International Cannabis Consortium; Social Science Genetic Association Consortium; Auton A, Boardman JD, Clark DW, Conlin A, Dolan CC, Fischbacher U, Groenen PJF, Harris KM, Hasler G, Hofman A, Ikram MA, Jain S, Karlsson R, Kessler RC, Kooyman M, MacKillop J, Männikkö M, Morcillo-Suarez C, McQueen MB, Schmidt KM, Smart MC, Sutter M, Thurik AR, Uitterlinden AG, White J, Wit H, Yang J, Bertram L, Boomsma DI, Esko T, Fehr E, Hinds DA, Johannesson M, Kumari M, Laibson D, Magnusson PKE, Meyer MN, Navarro A, Palmer AA, Pers TH, Posthuma D, Schunk D, Stein MB, Svento R, Tiemeier H, Timmers PRHJ, Turley P, Ursano RJ, Wagner GG, Wilson JF, Gratten J, Lee JJ, Cesarini D, Benjamin DJ, Koellinger PD, Beauchamp JP. Genome-wide association analyses of risk tolerance and risky behaviors in over 1 million individuals identify hundreds of loci and shared genetic influences. Nat Genet. 2019 Feb;51(2):245–257. doi: 10.1038/s41588-018-0309-3. Epub 2019 Jan 14. PMID: 30643258; PMCID: PMC6713272.30643258
50 Dave D, Saffer H. Alcohol demand and risk preference. J Econ Psychol. 2008 Dec;29(6):810–831. doi: 10.1016/j.joep.2008.03.006. PMID: 19956353; PMCID: PMC2636710.19956353
51 Umberson D, Crosnoe R, Reczek C. Social Relationships and Health Behavior Across Life Course. Annu Rev Sociol. 2010 Aug 1;36:139–157. doi: 10.1146/annurev-soc-070308-120011. PMID: 21921974; PMCID: PMC3171805.21921974
52 John Cawley, Christopher J. Ruhm, Chapter Three - The Economics of Risky Health Behaviors. Editor(s): Mark V. Pauly, Thomas G. Mcguire, Pedro P. Barros, Handbook of Health Economics, Elsevier, Volume 2, 2011, Pages 95–199. ISSN 1574-0064, ISBN 9780444535924. 10.1016/B978-0-444-53592-4.00003-7.
53 Wiseman, K.P., Seidenberg, A.B. & Klein, W.M.P. Clinician Role in Patient Awareness Regarding Carcinogenic Nature of Alcohol Consumption in the US: a Nationally Representative Survey. J GEN INTERN MED 37, 2116–2119 (2022). 10.1007/s11606-021-07113-9.34505982
54 “Unhealthy Alcohol Use in Adolescents and Adults: Screening and Behavioral Counseling Interventions.” U.S. Preventive Services Task Force, https://www.uspreventiveservicestaskforce.org/uspstf/recommendation/unhealthy-alcohol-use-in-adolescents-and-adults-screening-and-behavioral-counseling-interventions#toc. Accessed 24 August 2024.
55 Hammond D. Health warning messages on tobacco products: a review. Tob Control. Sep 2011;20(5):327–37. doi:10.1136/tc.2010.037630 21606180
56 U.S. Department of Health and Human Services. Smoking Cessation. A Report of the Surgeon General. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2020.
57 Zuckermann AME, Morissette K, Boland L, . The effects of alcohol container labels on consumption behaviour, knowledge, and support for labelling: a systematic review. Lancet Public Health. Jul 2024;9(7):e481–e494. doi:10.1016/s2468-2667(24)00097-5 38942559
58 Giesbrecht N, Reisdorfer E, Rios I. Alcohol Health Warning Labels: A Rapid Review with Action Recommendations. Int J Environ Res Public Health. Sep 16 2022;19(18) doi:10.3390/ijerph191811676
59 Joyce KM, Davidson M, Manly E, Stewart SH, Al-Hamdani M. A systematic review on the impact of alcohol warning labels. J Addict Dis. Jul–Sep 2024;42(3):170–193. doi:10.1080/10550887.2023.2210020 37212771
60 Kokole D, Anderson P, Jané-Llopis E. Nature and Potential Impact of Alcohol Health Warning Labels: A Scoping Review. Nutrients. 2021 Aug 31;13(9):3065. doi: 10.3390/nu13093065. PMID: 34578942; PMCID: PMC8469468.34578942
61 Hobin E, Weerasinghe A, Vallance K, . Testing Alcohol Labels as a Tool to Communicate Cancer Risk to Drinkers: A Real-World Quasi-Experimental Study. J Stud Alcohol Drugs. Mar 2020;81(2):249–261. doi:10.15288/jsad.2020.81.249 32359056
62 Noar, S. M., Francis, D. B., Bridges, C., Sontag, J. M., Brewer, N. T., & Ribisl, K. M. (2017). Effects of Strengthening Cigarette Pack Warnings on Attention and Message Processing: A Systematic Review. Journalism & Mass Communication Quarterly, 94(2), 416–442. 10.1177/1077699016674188 29975497
63 Global status report on alcohol and health 2018. Geneva: World Health Organization; 2018. Licence: CC BY-NC-SA 3.0 IGO
64 Stockwell T, Solomon R, O’Brien P, Vallance K, Hobin E. Cancer Warning Labels on Alcohol Containers: A Consumer’s Right to Know, a Government’s Responsibility to Inform, and an Industry’s Power to Thwart. J Stud Alcohol Drugs. 2020 Mar;81(2):284–292. PMID: 32359059.32359059
65 “Health warning labels on alcoholic beverages in the WHO European Region in 2024.” World Health Organization, who.int/docs/librariesprovider2/default-document-library/24-05-21_factsheet_labels.pdf. Accessed 21 November 2024.
66 Office of the Law Revision Counsel. “Subchapter II – Alcoholic Beverage Labeling.” United States Code, https://uscode.house.gov/view.xhtml?path=/prelim@title27/chapter8/subchapter2&edition=prelim. Accessed 21 November 2024.
67 “H.R.5210 - Anti-Drug Abuse Act of 1988.” Congress.gov, https://www.congress.gov/bill/100th-congress/house-bill/5210. Accessed 21 November 2024.