# About This Advisory

A Surgeon General’s Advisory is a public statement that calls the American people’s attention to an urgent public health issue and provides recommendations for how it should be addressed. Advisories are reserved for significant public health challenges that require the nation’s immediate awareness and action.

This document is not an exhaustive review of the literature. Rather, it was developed through a substantial review of the available evidence, primarily found via research published in English and resources suggested by a wide range of subject matter experts, with priority given to, but not limited to, meta-analyses and systematic literature reviews. The scope of this advisory is specific to alcohol use and cancer risk. It does not review broader health and societal outcomes associated with alcohol use. For additional background information, and to read other Surgeon General’s Advisories, visit SurgeonGeneral.gov (http://hhs.gov/surgeongeneral/reports-and-publications/)