# 3 We Can Take Action

There are actions we can take today to begin reducing alcohol-related cancers in the U.S. Key steps include:

- Update the existing Surgeon General’s health warning label on alcohol-containing beverages to include a warning about the risk of cancer associated with alcohol consumption. [See page 17]. Pursue changes to label characteristics to make the warning label more visible, prominent, and effective in increasing awareness about cancer risks associated with alcohol consumption.
- Reassess recommended limits for alcohol consumption to account for the latest evidence on alcohol consumption and cancer risk.
- Strengthen and expand education efforts to increase general awareness that alcohol consumption causes cancer.
- Inform patients in clinical settings about the link between alcohol consumption and increased cancer risk.^53^ Promote the use of alcohol screening and provide brief intervention and referral to treatment as needed.^54^
- Highlight alcohol consumption as a leading modifiable cancer risk factor and incorporate proven alcohol reduction strategies into population-level cancer prevention initiatives and plans.
- For individuals, be aware of the relationship between alcohol consumption and increased cancer risk when considering whether or how much to drink. Cancer risk increases as you drink more alcohol.

Additional Resources:

- The National Institute on Alcohol Abuse and Alcoholism’s Rethinking Drinking (https://rethinkingdrinking.niaaa.nih.gov/tools) initiative offers ways to evaluate your drinking and decide whether and how to make a change. In addition, CDC offers a free, interactive tool for you to check your drinking and get personalized feedback (in English (https://www.cdc.gov/alcohol/checkyourdrinking/index.html) and Spanish (https://www.cdc.gov/alcohol/evalua-su-consumo-de-alcohol/index.html)). Additionally, there are some individuals (https://www.dietaryguidelines.gov/sites/default/files/2020-12/Dietary_Guidelines_for_Americans_2020-2025.pdf) who should not drink at all.
- SAMHSA’s National Helpline is a free, confidential, 24/7, 365-day-a-year treatment referral and information service (in English (https://www.samhsa.gov/find-help/national-helpline) and Spanish (https://www.samhsa.gov/linea-nacional-ayuda)) for individuals and families facing mental health and/or substance use disorders.
- SAMHSA’s “Talk. They Hear You.” (https://www.samhsa.gov/talk-they-hear-you) campaign offers tips on how to talk to children and youth about alcohol.
- Learn more about key research gaps, such as those identified in this mini-review (https://aacrjournals.org/cebp/article/31/1/5/675488/Alcohol-and-Cancer-Existing-Knowledge-and-Evidence) in Cancer Epidemiology, Biomarkers & Prevention, to help advance the prevention of alcohol-related cancer.
- Addressing the broader population health impacts (https://www.cdc.gov/alcohol/about-alcohol-use/index.html) of alcohol consumption is beyond the scope of this Advisory. For more information on alcohol consumption and public health interventions, policies and solutions, please see information from CDC (https://www.cdc.gov/alcohol/prevention/proven-strategies.html) and WHO (https://iris.who.int/bitstream/handle/10665/259232/WHO-NMH-NVI-17.9-eng.pdf).

Updating Health Warning Labels on Alcoholic Beverages: An Important Next Step for Alcohol-Related Cancer Prevention

Health warning labels are well-established and effective approaches to increasing awareness of health hazards and fostering behavior change. Considerable evidence supports the use of health warning labels,^55,56^ including promising evidence toward their role in raising awareness about alcohol-related risks.^57–60^ For example, a natural experiment in Canada demonstrated that the inclusion of warning labels on alcohol beverage containers resulted in a 10% increase in knowledge about the association between alcohol and cancer after just two months of labeling.^61^ Additionally, scientific evidence has demonstrated that prominent, pictorial, and rotating messages, compared to less conspicuous, text-only, and static messages, are more effective for influencing awareness and behavior.^55–59,62^ There are 47 countries that require alcohol warning labels related to health and safety.^63^ South Korea requires a cancer-specific warning,^64^ and spurred by existing evidence, Ireland signed into law a new requirement to display a cancer warning label on alcohol-containing beverages starting in 2026.^65^ This label will state: “There is a direct link between alcohol and fatal cancers.”^65^

In the U.S., pursuant to 27 U.S.C. 215, every alcoholic beverage sold in the United States must currently have the following health warning label:

“GOVERNMENT WARNING: (1) According to the Surgeon General, women should not drink alcoholic beverages during pregnancy because of the risk of birth defects. (2) Consumption of alcoholic beverages impairs your ability to drive a car or operate machinery, and may cause health problems.”^66^

This label statement has remained unchanged since its inception in 1988.^67^

The power to change the label statement lies with Congress.^66^ Given the conclusive evidence on the cancer risk from alcohol consumption and the Office of the Surgeon General’s responsibility to inform the American public of the best available scientific evidence, the Surgeon General recommends an update to the Surgeon General’s warning label for alcohol-containing beverages to include a cancer risk warning.