# 2 The Causal Relationship Between Alcohol Consumption and Cancer: Summary of Evidence

Determining whether there is a causal relationship between a risk factor—a behavior, exposure, or characteristic—and a health outcome such as cancer is done through comprehensive assessments of scientific evidence and the application of well-established scientific criteria, such as the Bradford Hill criteria.^16–21^

This scientific approach includes assessing the relationship between the risk factor (e.g., alcohol consumption) and the subsequent occurrence of a disease outcome (e.g., cancer) in observational studies where large numbers of people are followed over time. It also includes careful review of the effect of the risk factor in animal studies and research to understand the biological and chemical pathways leading to cancer. This is the same approach that was used to conclude that cigarette smoking causes lung cancer^17^ and is the same approach that has established alcohol consumption as a cause of cancer.

Over the last two decades, numerous high-quality observational studies and meta-analytic reviews have assessed and observed a significant relationship between alcohol consumption and increased cancer risk.^6–11,22^ A global meta-analysis of 572 studies examining data from 486,538 cancer cases resulted in findings consistent with this conclusion.^10^ An additional pooled analysis of 26 studies found that the relative odds of mouth cancer increased by 40% for those who consumed about one drink daily compared to those who did not drink.^c,9^ Another pooled analysis of 20 cohorts of more than one million women found that the relative risk of breast cancer increased by 10% for women who consumed up to about one drink daily compared to those who did not drink.^8^ Further, a global study of 195 countries and territories involving 28 million individuals found that higher levels of alcohol consumption were associated with greater risk of cancer.^11^ Extensive research has demonstrated specific biological mechanisms by which alcohol causes cancer as well. For example, multiple studies have shown that giving rats and mice drinking water with ethanol (the same type of pure alcohol in alcohol-containing beverages) or its primary metabolic breakdown product, acetaldehyde, results in increased tumor numbers at multiple places in the body.^7^ At high levels such as those that occur with consumption of alcohol, acetaldehyde is highly toxic and cancer-causing.^23–27^

Further, the data in humans on alcohol and health show a strong association between drinking alcohol and increased cancer risk, regardless of the type of alcohol (e.g., beer, wine, and spirits).^6,28^ Cumulatively, rigorous research, across observational, biological, and genetic studies, has shown that alcohol consumption increases the risk of cancer for at least seven sites: breast (in women), colorectum, esophagus, liver, mouth (oral cavity), throat (pharynx), and voice box (larynx) (Figure 3).^6,7^

The two most prominent international organizations that review evidence for carcinogenicity attribute the highest level of causal evidence to the association between alcohol consumption and the development of cancer. The International Agency for Research on Cancer (IARC), which is the specialized cancer agency of the World Health Organization (WHO), classifies alcohol as a Group 1 carcinogen—alongside tobacco, asbestos, and formaldehyde, among others—the highest level of classification by IARC for when “there is enough evidence to conclude that it can cause cancer in humans.”^29^ Similarly, the World Cancer Research Fund/American Institute for Cancer Research (WCRF/AICR) ranks the evidence linking alcohol and cancer as “Convincing: Increases Risk,” also their highest ranking.^6^ Additionally, the U.S. National Toxicology Program concluded in 2000 that “Alcoholic Beverage Consumption” is known to be a human carcinogen.^22^ This body of conclusive evidence that alcohol causes at least seven types of cancer is also agreed upon by the Centers for Disease Control and Prevention (CDC) and the National Institutes of Health’s National Cancer Institute (NCI).^28,30^

The association between alcohol use and cancer is also documented in U.S. federal reports, including the 2016 Surgeon General’s Report on Alcohol, Drugs, and Health, which indicates that alcohol misuse is associated with:^31^

“… cancers of the oral cavity, esophagus, larynx, pharynx, liver, colon, and rectum. Even one drink per day may increase the risk of breast cancer.”

Alcohol-related harms, including cancer, are further discussed in the 2020-2025 Dietary Guidelines for Americans, which indicates:^15^

“Emerging evidence suggests that even drinking within the recommended limits may increase the overall risk of death from various causes, such as from several types of cancer and some forms of cardiovascular disease. Alcohol has been found to increase risk for cancer, and for some types of cancer, the risk increases even at low levels of alcohol consumption (less than 1 drink in a day). Caution, therefore, is recommended.”

FIGURE 3 Consuming alcohol increases the risk of developing at least 7 types of cancer

An anatomy diagram with the title: Consuming alcohol increases the risk of developing at least 7 types of cancer

While the causal relationship between alcohol consumption and cancer is firmly established,^6,7,22^ further research is needed on the potential effect of alcohol consumption on increasing cancer risk at additional sites such as skin, prostate, pancreas, and stomach,^28,32,33^ and decreased risk for sites such as kidney.^32,33^ More research is also needed to determine how specific drinking patterns (e.g., binge vs. non-binge drinking) may affect cancer risk as well as how drinking at specific ages and during certain developmental periods, such as in adolescence and older adulthood, may influence the risk of cancer.^34^

## How does alcohol cause cancer?

There is extensive evidence from biological studies that ethanol (the type of pure alcohol found in all alcohol-containing beverages) causes cancer in at least four distinct ways (Figure 4).^7,23,24,29,35–38^

- First, alcohol breaks down into acetaldehyde in the body. Acetaldehyde is a metabolite that causes cancer by binding to DNA and damaging it. When DNA is damaged, a cell can begin to grow uncontrollably and create a cancerous tumor.
- Second, alcohol generates reactive oxygen species, which increase inflammation and can damage DNA, proteins, and lipids in the body through a process called oxidation.
- Third, alcohol alters hormone levels (including estrogen), which can play a role in the development of breast cancer.
- Fourth, carcinogens from other sources, especially particles of tobacco smoke, can dissolve in alcohol, making it easier for them to be absorbed into the body, increasing the risk for mouth and throat cancers.

The best-established evidence is on the first two pathways of acetaldehyde and inflammation. Hormonal regulation and alcohol as a solvent are widely agreed upon to be important pathways for carcinogenesis but are not yet fully understood. Research also continues on other possible mechanisms, including folate deficiency, by which alcohol can cause cancer.

FIGURE 4 Four ways alcohol can cause cancer

Four diagrams of mechanisms with the title: Four ways alcohol can cause cancer

## How does the amount of alcohol you consume affect your risk of cancer?

The amount of alcohol a person drinks affects their risk of cancer. An important factor is the overall amount of alcohol consumed consistently over time. The risk of cancer increases as the level of consumption increases with higher risk at higher levels of consumption. For certain cancers, like breast, mouth, and throat cancers, evidence shows that this risk may start to increase around one or fewer drinks per day.^6,8–10^

Ways of Understanding Risk

Absolute risk is the actual chance, or probability, of an outcome occurring (e.g., a new cancer diagnosis).^39^ Relative risk is the proportional chance of an outcome occurring for one group (e.g. those who drink alcohol) as compared to another group (e.g. those who do not drink alcohol).^39^ It is important to understand that a large change in relative risk may represent only a small change in absolute risk. For example, the absolute risk of drowning in the United States is about 1 out of 1000.^40^ If a behavior increased the relative risk of drowning by 100%, this would result in an absolute risk of 2 out of 1000. This might not seem that large but is a doubling of absolute risk compared to the baseline risk of 1 out of 1000. Both absolute and relative risk estimates can be helpful in understanding risk.

One way to understand the significance of this cancer risk is to look at the absolute risk of developing cancer over time among those who consume alcohol in different quantities (Figures 5 and 6). For example, a study of 226,162 individuals^d^ reported that the absolute risk of developing any alcohol-related cancer over the lifespan of a woman increases from approximately 16.5% (about 17 out of every 100 individuals) for those who consume less than one drink per week, to 19.0% (19 out of every 100 individuals) for those who consume one drink daily on average to approximately 21.8% (about 22 out of every 100 individuals) for those who consume two drinks daily on average (Figure 5).^41^ That is about five more women out of 100 who would have developed cancer due to a higher level of alcohol consumption. Additionally, the absolute risk of breast cancer over the lifespan of a woman is approximately 11.3% (about 11 out of 100 individuals) for those who consume less than one drink per week compared to 13.1% (about 13 out of 100 individuals) or 15.3% (about 15 out of 100 individuals) for those who consume one or two drinks per day, respectively (Figure 6).^41^

Over the lifespan of a man, the absolute risk of developing any alcohol-related cancer increases from approximately 10.0% (about 10 out of every 100 individuals) for those who consume less than one drink per week to about 11.4% (about 11 out of every 100 individuals) for those who consume one drink daily on average to approximately 13.1% (about 13 out of every 100 individuals) for those who consume two drinks daily on average (Figure 5).^41^

FIGURE 5 Higher alcohol consumption increases alcohol-related cancer risk in women and men

Two bar charts labeled Women and Men with the title: Higher alcohol consumption increases alcohol-related cancer risk in women and men

FIGURE 6 Higher alcohol consumption increases breast cancer risk in women

A bar chart with the title: Higher alcohol consumption increases breast cancer risk in women

Another way to understand this risk is to look at the relative risk of developing cancer from alcohol consumption for those who drink compared to those who do not drink. One analysis found a 10% relative risk increase in breast cancer for women who consume up to about one drink per day, and a 32% relative risk increase for women who consume more than two drinks per day, compared to women who did not drink.^8^ Because many U.S. adults consume alcohol,^3,42^ and because breast cancer in particular is among the most common of cancers,^43^ this constitutes a substantial number of preventable cancer cases. Another analysis in men and women found a 40% relative odds increase for mouth cancer for those drinking about one drink per day and a 97% relative odds increase for those drinking about two drinks per day,^e^ compared to those who did not drink (note: the lifetime absolute risk of developing mouth is about 0.8%).^f,9^ In other words, the absolute risk of mouth cancer for men and women who average two drinks daily is nearly twice as high as the risk for non-drinkers. Because mouth cancer is less common than breast cancer, mouth cancer cases do not account for as many alcohol-related cancer cases as breast cancer cases.

By contrast, long-term quitting or reduced drinking are associated with lower risks of some alcohol-related cancers. A recent evidence review conducted by IARC concluded that alcohol cessation or reduction decreased the risk of mouth cancer and esophageal cancer.^44,45^ More research is needed to determine if this risk decreases for other cancer sites and whether it decreases to the level observed in people who never consume alcohol.^44,45^

Importantly, the risks presented above are average risks based on the studied populations. An individual’s risk for developing cancer, including alcohol-related cancers, varies and is determined by a complex interaction of biological factors (e.g., genetics) and environmental factors (e.g., exposure to carcinogens). For example, many individuals of East Asian descent have a genetic variant that results in an alcohol flushing response and reduces their ability to metabolize acetaldehyde, which produces much higher risks for certain alcohol-related cancers.^46–48^ In addition, an individual’s alcohol consumption level and associated cancer risk may be influenced by social and economic factors, including social norms, peer pressure, advertising, and other commercial activities. Individuals may also have different comfort levels (risk tolerances) when it comes to taking different types of risks, including alcohol consumption.^49–52^

c The odds reported occurred from alcohol consumption of 12g daily over a 5 year duration.

d Cumulative absolute risk of seven alcohol-related cancers over the lifespan up to age 80 were calculated using results from Sarich (2021). Continuous log-linear hazard ratios from Cox proportional hazard models based on the Australian 45 and Up cohort (n = 226,162) were applied to cancer rates observed for people reporting 0 to <1 drink/week, to calculate the absolute risk for consuming 7 and 14 US drinks/week (1 and 2 US drinks/day). These estimates differ in how they were calculated from the results reported in Sarich et al. because the continuous model was used rather than hazard ratios for the specific consumption categories. All hazard models were adjusted for sex, education, household income, health insurance status, partner status, country of birth, smoking status and intensity, body mass index and physical activity. Additional covariates were included for specific cancers. For these models, the reference group included very light drinkers, but not non-drinkers to avoid the sick quitter effect.

e This study reports odds ratios (also called relative odds), a measure of risk comparable to relative risk when disease outcomes are not very common. The odds reported occurred from alcohol consumption of 12g daily over a 5 year duration.

f Based on data (https://seer.cancer.gov/statistics-network/explorer) from the National Cancer Institute