# 1 Alcohol Consumption is a Leading Preventable Cause of Cancer

Alcohol consumption is the third leading preventable cause of cancer in the United States, after tobacco and obesity.^1^

In 2019, an estimated 96,730 cancer cases were related to alcohol consumption including 42,400 in men and 54,330 in women. This translates to nearly 1 million^1^ preventable cancer cases over ten years in the U.S. The largest burden of alcohol-related cancer in the U.S. is for breast cancer in women with an estimated 44,180 cases in 2019, representing 16.4% of the approximately 270,000 total breast cancer cases for women. Globally, 741,300 cancer cases were related to^1^ alcohol consumption in 2020; 185,100 of those cases were related to consumption of approximately two drinks daily or fewer (Figure 1).^12^

FIGURE 1 741,300 cancer cases worldwide were attributable to alcohol consumption in 2020

A pie chart with the title: 741,300 cancer cases worldwide were attributed to alcohol consumption in 2020

In the U.S., there are about 20,000 alcohol-related cancer deaths annually.^1,2^ This is greater than the number of alcohol-associated traffic crash fatalities (about 13,500 annually) in the U.S.^a,13^ Alcohol-related cancer deaths shorten the lives of those who die by an average of 15 years.^14^ Annually, a total of about 305,000 years of potential life are lost due to alcohol-related cancer deaths.^14^ Breast cancer accounts for the majority (~60%) of alcohol-related cancer deaths in women, whereas liver cancer (~33%) together with colorectal cancer (an additional ~21%) account for the majority of alcohol-related cancer deaths in men.^2^ About 83% of the estimated 20,000 U.S. alcohol-related cancer deaths per year occur at levels above the 2020-2025 U.S. Dietary Guidelines for Americans recommended limits of two drinks daily for men and one drink daily for women.^2,15^ Nonetheless, the remaining 17% of the estimated 20,000 U.S. alcohol-related cancer deaths per year occur at levels within those recommended limits.^2^

Despite clear evidence demonstrating the effect of alcohol consumption on cancer risk, there is a large gap in public understanding of the risk. In a 2019 survey, 45% of Americans recognized alcohol use as a risk factor for cancer compared to 91% of Americans who recognized the risk of radiation exposure, 89% for tobacco use, 81% for asbestos exposure, and 53% for obesity (Figure 2).^b,4^ Additionally, public awareness of alcohol consumption as a cancer risk factor has not substantially improved over nearly two decades,^4^ even as evidence documenting the link between alcohol consumption and cancer risk has increased.

FIGURE 2 Less than half of Americans are aware that alcohol consumption increases cancer risk

A bar chart with the title: Less than half of Americans are aware that alcohol consumption increases cancer risk

a Alcohol-associated traffic crash fatalities include impaired drivers and passengers/victims of crashes.

b Other recent survey data demonstrate comparable alcohol consumption and cancer awareness estimates ranging from about 30-50% from the National Center for Health Statistics (https://www.cdc.gov/nchs/rss/round1/cancer-risks.html) and the Health Information National Trends Survey (https://hints.cancer.gov/docs/Briefs/HINTS_Brief_47.pdf).