# Acknowledgments

The U.S. Surgeon General’s Advisory on Alcohol and Cancer Risk was prepared by the Office of the Surgeon General with valuable contributions from partners across the U.S. Government, including but not limited to:

- Assistant Secretary for Planning and Evaluation (ASPE)
- Centers for Disease Control and Prevention (CDC)
- Centers for Medicaid & Medicare Services (CMS)
- Food and Drug Administration (FDA)
- Indian Health Service (IHS)
- Office of the Assistant Secretary for Health (OASH)
- Office of the General Counsel (OGC)
- National Institutes of Health (NIH)
- Substance Abuse and Mental Health Services Administration (SAMHSA)