# FOREWORD FROM THE PRINCIPAL DEPUTY ADMINISTRATOR, SUBSTANCE ABUSE AND MENTAL HEALTH SERVICES ADMINISTRATION

Photograph of Kana Enomoto.

Substance misuse is one of the critical public health problems of our time. The most recent data on substance use, misuse, and substance use disorders reveal that the problem is deepening and the consequences are becoming more deadly than ever. There is an urgent need to raise awareness about the issue. At the same time, we need to spread the word that substance misuse and addiction are solvable problems. We can, and must, inspire and catalyze action on this crisis.

That's why I am so proud to support the Office of the Surgeon General in releasing this first report of its kind – The Surgeon General's Report on Alcohol, Drugs, and Health.

This Report takes a comprehensive look at the problem; covering topics including misuse of alcohol, prescription drugs, and other substances, and bringing together the best available science on the adverse health consequences of substance misuse. It also summarizes what we know about what works in prevention, treatment, and recovery. Our goal: to equip health care providers, communities, policymakers, law enforcement, and others with the evidence, the tools, and the information they need to take action to address this growing epidemic.

Now is the time for this Report. The substance misuse problem in America won't wait. Almost 22.5 million people reported use of an illegal drug in the prior year. Over 20 million people have substance use disorders, and 12.5 million Americans reported misusing prescription pain relievers in the past year. Seventy-eight people die every day in the United States from an opioid overdose, and those numbers have nearly quadrupled since 1999. Despite the fact that we have treatments we know are effective, only one in five people who currently need treatment for opioid use disorders is actually receiving it.

The addiction problem touches us all. We all need to play a part in solving it. The Surgeon General's Report on Alcohol, Drugs, and Health provides a roadmap for working together to move our efforts forward. I hope all who read it will be inspired to take action to stem the rising tide of this public health crisis and reduce the impact of substance misuse and addiction on individuals, communities, and our nation.

- Kana Enomoto
  Principal Deputy Administrator
  Substance Abuse and Mental Health Services Administration
  U.S. Department of Health and Human Services