# ACKNOWLEDGMENTS

This Report was prepared by the U.S. Department of Health and Human Services under the general direction of the Substance Abuse and Mental Health Services Administration.

Vice Admiral Vivek H. Murthy, M.D., M.B.A., Surgeon General, U.S. Public Health Service, Office of the Surgeon General, Office of the Assistant Secretary for Health, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Kana Enomoto, Principal Deputy Administrator, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.

## Science Editors

- A. Thomas McLellan, Ph.D., Senior Scientific Editor, Chair of the Board and Co-Founder, Treatment Research Institute, Philadelphia, Pennsylvania.
- Richard F. Catalano, Jr., Ph.D., M.A., Bartley Dobb Professor for the Study and Prevention of Violence; Co-Founder, Social Development Research Group, School of Social Work, University of Washington, Seattle, Washington.
- H. Westley Clark, M.D., J.D., M.P.H., CAS, FASAM, Dean's Executive Professor of Public Health, Santa Clara University, Santa Clara, California.
- Keith Humphreys, Ph.D., Professor, Department of Psychiatry and Behavioral Science, Stanford University, Stanford, California; Research Career Scientist, VA Palo Alto Health Care System, Palo Alto, California.
- George F. Koob, Ph.D., Director, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- Nora D. Volkow, M.D., Director, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Constance M. Weisner, Dr.P.H., M.S.W., Associate Director, Behavioral Health, Aging, and Infectious Disease Section, Division of Research, Kaiser Permanente, Oakland, California; Professor of Psychiatry, Department of Psychiatry, Langley Porter Psychiatric Institute, University of California, San Francisco, California.

## Managing Editors

- Jinhee J. Lee, Pharm.D., Managing Editor, Senior Public Health Advisor, Division of Pharmacologic Therapies, Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Jorielle Brown Houston, Ph.D., Associate Managing Editor, Director, Division of Systems Development, Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Richard Lucey, Jr., M.A., Associate Managing Editor, Special Assistant to the Director, Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.

## Contributing Editors

- Nazleen H. Bharmal, M.D., Ph.D., M.P.P., Director of Science and Policy, Office of the Surgeon General, Office of the Assistant Secretary of Health, U.S. Department of Health and Human Services, Washington, D.C.
- Christine A. Cichetti, Senior Behavioral Health Policy Advisor, Office of the Assistant Secretary for Health/Office of the Deputy Assistant Secretary for Health (Science and Medicine), Washington, D.C.
- Tom Coderre, Chief of Staff, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Tom Hill, M.S.W., Senior Advisor for Addiction and Recovery, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Marion Cornelius Pierce, Public Health Analyst, Division of Systems Development, Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.

## Contributing Authors

- Michael A. Arends, Senior Research Assistant in the Committee on the Neurobiology of Addictive Disorders, The Scripps Research Institute, La Jolla, California.
- Maureen Boyle, Ph.D., Chief, Science Policy Branch, Office of Science Policy and Communications, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Felipe González Castro, Ph.D., M.S.W., Professor and Southwest Borderlands Scholar, Arizona State University, College of Nursing and Health Innovation, Phoenix, Arizona.
- Mady Chalk, Ph.D., M.S.W., Managing Partner, The Chalk Group.
- Laura J. Dunlap, Ph.D., Director, Behavioral Health Economics Program, RTI International, Research Triangle Park, North Carolina.
- Vivian B. Faden, Ph.D., Director, Office of Science Policy and Communications and Associate Director of Behavioral Research, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- Abigail A. Fagan, Ph.D., Associate Professor of Criminology & Law, Department of Sociology and Criminology & Law, University of Florida, Gainesville, Florida.
- Mark T. Greenberg, Ph.D., M.A., Edna Peterson Bennett Endowed Chair in Prevention Research, Professor of Human Development and Psychology, College of Health and Human Development, The Pennsylvania State University, State College, Pennsylvania.
- Kevin P. Haggerty, Ph.D., M.S.W., Associate Professor; Director of Research; Director, Social Development Research Group; School of Social Work, University of Washington, Seattle, Washington.
- Ralph W Hingson, Sc.D., M.P.H., Director, Division of Epidemiology and Prevention Research, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- Jennifer A. Hobin, Ph.D., Senior Health Science Policy Analyst, Science Policy Branch, Office of Science Policy and Communications, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- John F. Kelly, Ph.D, Elizabeth R Spallin Associate Professor of Psychiatry in the Field of Addiction Medicine, Harvard Medical School, Boston, Massachusetts; Director, Recovery Research Institute; Program Director, Addiction Recovery Management Service; Associate Director, Center for Addiction Medicine, Massachusetts General Hospital, Boston, Massachusetts.
- Tami L. Mark, Ph.D., M.B.A., Vice President and Director, Center for Behavioral Health Services Research, Truven Health Analytics, Bethesda, Maryland.
- Patrick O'Connor, M.D., M.P.H., F.A.C.P., Professor and Chief of General Internal Medicine, Yale University School of Medicine, New Haven, Connecticut.
- Harold Pollack, Ph.D., M.P.P., Helen Ross Professor, School of Social Services Administration; Affiliate Professor, Biological Science Collegiate Divisions and the Department of Public Health Service; Co-Director, The University of Chicago Crime Lab, The University of Chicago, Chicago, Illinois.
- Patricia A. Powell, Ph.D., Acting Deputy Director, Associate Director for Scientific Initiatives, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- Stacy A. Sterling, Dr.P.H., M.S.W., Practice Leader, Division of Research, Kaiser Permanente, Oakland, California.
- Eric M. Wargo, Ph.D., Science Writer, Science Policy Branch, Office of Science Policy and Communications, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Deborah Klein Walker, Ed.D., Vice President & Senior Fellow, U.S. Health, Abt Associates, Cambridge, Massachusetts.
- Bridget D. Williams-Simmons, Ph.D., Chief, Science Policy Branch, Office of Science Policy and Communications, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- Gary A. Zarkin, Ph.D., Vice President, Behavioral Health and Criminal Justice Research Division, RTI International, Research Triangle Park, North Carolina.

## Science Writer

- Anne B. Rodgers, Science Writer, Falls Church, Virginia.

## Reviewers

- Hortensia Amaro, Ph.D., Dean's Professor, School of Social Work; Professor, Department of Preventive Medicine, Keck School of Medicine; and Associate Vice Provost, Community Research Initiatives, University of Southern California, Los Angeles, California.
- Trina Menden Anglin, M.D., Ph.D., Chief, Adolescent Health Branch, Maternal and Child Health Bureau, Health Resources and Services Administration, Rockville, Maryland.
- Bethany Applebaum, M.P.H., M.A., Public Health Analyst, Office of Women's Health, Health Resources and Services Administration, Rockville, Maryland.
- Marsha L. Baker, LCSW, Public Health Advisor, Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- David S. Barry, Psy.D., Public Health Advisor, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Mirtha R Beadle, Director, Office of Tribal Affairs and Policy, Office of Policy, Planning, and Innovation, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- David J. Beckstead, Ph.D., A.P.B.B., Clinical Director, Desert Visions Youth Wellness Center, Indian Health Services, Sacaton, Arizona.
- B. Steven Bentsen, M.D., D.F.A.P.A., Regional Chief Medical Officer, Beacon Health Options, Morrisville, North Carolina.
- Mitchell Berger, Public Health Advisor, Office of Policy, Planning, and Innovation, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Jonaki Bose, Branch Chief, Populations Survey Branch, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Cheryl A. Boyce, Ph.D., Division of Clinical Neuroscience and Behavioral Research, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Katharine A. Bradley, M.D., M.P.H., Senior Investigator and Internal Medicine Physician, Group Health Research Institute, Seattle, Washington.
- Robert D. Brewer, M.D., M.S.P.H., Epidemiologist - Lead, Alcohol Program, Division of Population Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Jeffrey A. Buck, Ph.D., Centers for Medicare & Medicaid Services, Washington, D.C
- A. Kathleen Burlew, Ph.D., M.A., McMicken Professor, McMicken College of Arts and Sciences, University of Cincinnati, Cincinnati, Ohio.
- John Campbell, M.A., Chief, Performance Partnership Grant Branch, Division of State and Community Assistance, Chief Medical Officer, Office of the Director, Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Melinda Campopiano, M.D., Chief Medical Officer, Office of the Director, Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Christopher D. Carroll, M.Sc., Director of Health Care Financing and Systems Integration, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Walter B. Castle, M.S.S.W., Senior Public Health Advisor, Division of Behavioral Health, Indian Health Service, Rockville, Maryland.
- Nancy Cheal, M.S., Ph.D., Health Scientist, Division of Congenital and Developmental Disorders, National Center on Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Laura W. Cheever, M.D., Sc.M., Associate Administrator, HIV/AIDS Bureau, Health Resources and Services Administration, Rockville, Maryland.
- Dominic Chiapperino, Ph.D., Regulatory and Liaison Team Lead, Controlled Substance Staff, Center for Drug Evaluation and Research, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Wilson M. Compton, M.D., M.P.E., Deputy Director, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Jessica H. Cotto, Health Scientist Administrator, Science Policy Branch, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Don L Coyhis, Mohican Nation, President and Founder, White Bison, Inc., Colorado Springs, Colorado.
- Steven Dettwyler, Ph.D., Public Health Advisor, State Grants Western Branch, Division of State and Community Systems Development, Center for Mental Health Services, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Lori Ducharme, Ph.D., Program Director for Health Services Research, Division of Treatment and Recovery Research, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- Marissa Esser, M.P.H., Ph.D., Heath Scientist, Division of Population Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Monica Feit, Ph.D., Director of the Office of Policy, Planning, and Innovation, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Corinne Ferdon, Ph.D., Deputy Associate Director for Science, Division of Violence Prevention, National Center for Injury Prevention and Control, Centers for Disease Control and Prevention, Atlanta, Georgia.
- David A. Fiellin, M.D., Professor of Medicine (General Medicine) and Public Health (Health Policy), Institute for Social and Policy Studies; Director, Community Research and Implementation Core, Center for Interdisciplinary Research on AIDS, Yale School of Medicine, New Haven, Connecticut.
- Pennie Foster-Fishman, Ph.D., Professor, Department of Psychology; Senior Outreach Fellow, University Outreach and Engagement, Michigan State University. East Lansing, Michigan.
- Henry L. Francis, M.D., Director for Data Mining and Informatics Evaluation and Research, Office of Translational Sciences, Center for Drug Evaluation and Research, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Rebecca Freeman, Ph.D., R.N., P.M.P., Chief Nursing Officer, Office of the National Coordinator for Health IT, U.S. Department of Health and Human Services, Washington, D.C
- Peter Gaumond, Chief, Recovery Branch, Office of National Drug Control Policy, Executive Office of the President, Washington, D.C.
- Udi E. Ghitza, Ph.D., Health Scientist Administrator, Program Officer, Center for the Clinical Trials Network, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Gregory Goldstein, M.S.H.S., Deputy Director, Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Althea M. Grant, M.P.H., Ph.D., Chief, Epidemiology and Surveillance Branch, Division of Blood Disorders, National Center on Birth Defects and Developmental Disabilities, Office of Noncommunicable Diseases, Injury and Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Stephen J. Gumbley, M.A., Independent Consultant; Former Director, New England Addiction Technology Transfer Center, Providence, Rhode Island.
- Susan Marsiglia Gray, M.P.H., Senior Public Health Advisor, Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Frances M. Harding, Director, Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- R Adron Harris, Ph.D., M.June & J. Virgil Waggoner Chair in Molecular Biology; Director, Waggoner Center for Alcohol and Addiction Research, University of Texas at Austin, Austin, Texas.
- Marla Hendriksson, M.P.M., Director, Office of Communications, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Anne M. Herron, M.S., Director, Division of Regional and National Policy Liaison, and Agency Lead, SAMHSA Workforce Development Strategic Initiative, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Sharon Hertz, M.D., Director, Division of Anesthesia, Analgesia, and Addiction Products, Center for Drug Evaluation and Research, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Kevin C. Heslin, Ph.D., Staff Research Fellow, Agency for Healthcare Research and Quality, U.S. Department of Health and Human Services, Rockville, Maryland.
- Donna Hillman, M.A., Lead Public Health Advisor, Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Margaret (Peggy) Honein, Ph.D., M.P.H., Chief, Birth Defects Branch, National Center on Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Alexis G. Horan, M.P.P., Expert Consultant, Addiction Policy, Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services, Washington, D.C
- Constance M. Horgan, M.A., Sc.D., Professor; Director, Institute for Behavioral Health, The Heller School for Social Policy and Management, Brandeis University, Waltham, Massachusetts.
- Larke N. Huang, Ph.D., Director, Office of Behavioral Health Equity, Office of Policy, Planning, and Innovation, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Robert B. Huebner, Ph.D., Acting Director, Division of Treatment and Recovery Research, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- Kristen V. Huntley Ph.D., Health Science Administrator, Center for the Clinical Trials Network, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Corinne G. Husten, M.D., M.P.H., Senior Medical Advisor, Office of the Center Director, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Linda Hutchings, M.S.J., Special Assistant to the Director, Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Pamela S. Hyde, J.D., Former Administrator, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Carrie L. Jeffries, A.N.P.-B.C., M.S., M.P.H., R.N., A.A.C.R.N., Chief Nursing Officer, HIV/AIDS Bureau, Health Resources and Services Administration, Rockville, Maryland.
- Amelia (Amy) Jewett, M.P.H., Epidemiologist, Transportation Safety Team, Division of Unintentional Injury Prevention, National Center for Injury Prevention and Control, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Kimberly A. Johnson, Ph.D., Director, Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Wanda K. Jones, Dr.P.H., M.P.H., Principal Deputy Assistant Secretary for Health, U.S. Department of Health and Human Services, Washington, D.C.
- Elliot Kennedy, J.D., Special Expert, LGBT Affairs, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Paul J. Kenny, Ph.D., Ward-Coleman Professor; Chair, Dorothy H. and Lewis Rosentiel Department of Pharmacology and Systems Therapeutics; Director, Experimental Therapeutics Institute, Mount Sinai Hospital, New York, New York.
- Thomas Kresina, Ph.D., Senior Public Health Advisor, Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Alexandre B. Laudet, Ph.D., Director, Center for the Study of Addictions and Recovery, National Development and Research Institutes, Inc. (NDRI), New York, New York.
- Jennifer LeClercq, M.P.H., C.H.E.S., Public Health Analyst, Division of Population Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Raye Z. Litten, Ph.D., Acting Director, Division of Medications Development, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- Xiang Sharon Liu, Statistician, Treatment Service Branch, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Jacqueline J. Lloyd, Ph.D., M.S.W., Deputy Branch Chief and Health Scientist Administrator, Prevention Research Branch, Division of Epidemiology, Services, and Prevention Research, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Joshua Lloyd, M.D., Lead Medical Officer, Division of Anesthesia, Analgesia, and Addiction Products, Center for Drug Evaluation and Research, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Peter G. Lurie, M.D., M.P.H., Associate Commissioner for Public Health Strategy and Analysis, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Robert Lyerla, Ph.D., Research Officer, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Spero M. Manson, Ph.D., Distinguished Professor of Public Health and Psychiatry; Director, Centers for American Indian and Alaska Native Health; The Colorado Trust Chair in American Indian Health; Associate Dean of Research, Colorado School of Public Health, Aurora, Colorado.
- Tim McAfee, Director, Medical Officer, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Dennis McCarty, Ph.D., M.A., Professor; Division Head, Health Services Research; OHSU-PSU School of Public Health, Oregon Health & Science University, Portland, Oregon.
- David K. Mineta, M.S.W., President and CEO, Momentum for Mental Health, San Jose, California.
- Ivan D. Montoya, M.D., M.P.H., Deputy Director, Division of Therapeutics and Medical Consequences, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Michele LaTour Monroe, Senior Communications Specialist, Office of Communications, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Jon Morgenstern, Ph.D., Director of Addiction Services, Northwell Health, Great Neck, New York.
- Charlotte A. Mullican, M.P.H., Senior Advisor for Mental Health Research, Center for Evidence and Practice Improvement, Agency for Healthcare Research and Quality, Rockville, Maryland.
- Lisa M. Najavits, Ph.D., Professor, Department of Psychiatry, Boston University School of Medicine, Boston, Massachusetts; Director, Treatment Innovations, Newton Centre, Massachusetts.
- Jon P. Nelson, Ph.D., Professor Emeritus of Economics, The Pennsylvania State University, State College, Pennsylvania.
- Phyllis Holditch Niolon, Ph.D., Behavioral Scientist, Division of Violence Prevention, National Center for Injury Prevention and Control, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Antonio Noronha, Ph.D., Director, Division of Neuroscience and Behavior, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- Thomas E. Novotny, M.D., M.P.H., Deputy Assistant Secretary for Health (Science and Medicine), U.S. Department of Health and Human Services, Washington, D.C.
- John P. O'Brien, Senior Policy Advisor, Disabled and Elderly Health Programs Group, Centers for Medicare & Medicaid Services, Baltimore, Maryland.
- David L. Olds, Ph.D., Professor of Pediatrics; Director, Prevention Research Center for Family and Child Health; Department of Pediatrics, University of Colorado, Aurora, Colorado.
- Dee S. Owens, M.P.A., Special Assistant to the Director, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Derek W. Patton, M.S., M.B.A., Division Director, Integrated Behavioral Health, Office of Health Programs, Indian Health Service, Phoenix, Arizona.
- Len Paulozzi, M.D., Medical Officer, Division of Unintentional Injury Prevention, National Center for Injury Prevention and Control, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Adolf Pfefferbaum, M.D., Senior Program Director and Distinguished Scientist, Center for Health Sciences, SRI International, Menlo Park, California.
- Kathryn Piscopo, Ph.D., Survey Statistician, Populations Survey Branch, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Jean O. Plascke, M.S.W., Youth Programs Officer, Office of Indian Alcohol and Substance Abuse, Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Richard A. Rawson, Ph.D., Research Professor, Department of Psychiatry, University of Vermont, Burlington, Vermont; Professor Emeritus Department of Psychiatry; Geffen School of Medicine, University of California, Los Angeles, California.
- Kenneth W. Robertson, Lead Public Health Advisor, Criminal Justice Grants, Targeted Populations Branch, Division of Systems Improvement, Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Susan Robilotto, D.O., Clinical Advisor/Medical Officer, HIV/AIDS Bureau, Health Resources and Services Administration, Rockville, Maryland.
- Letitia B. Robinson, Ph.D., R.N., Senior Advisor, HIV/AIDS Bureau, Health Resources and Services Administration, Rockville, Maryland.
- Alexander F. Ross, Sc.D., Senior Behavioral Health Advisor, Office of Planning, Evaluation, and Analysis, Health Resources and Services Administration, Rockville, Maryland.
- Tyler Sadwith, Health Insurance Specialist, Center for Medicaid and CHIP Services, Centers for Medicare & Medicaid Services, San Francisco, California.
- Onaje M. Salim, M.A., Ed.D., Director, Division of State and Community Assistance, Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- David R Shillcutt, J.D., Disabled and Elderly Health Programs Group, Center for Medicaid and CHIP Services, Centers for Medicare & Medicaid Services, Baltimore, Maryland.
- Ruth Shults, Ph.D., M.P.H., Senior Epidemiologist, Division of Unintentional Injury Prevention, National Center for Injury Prevention and Control, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Belinda Sims, Ph.D., Health Scientist Administrator, Prevention Research Branch, Division of Epidemiology, Services and Prevention Research, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Geetha A. Subramaniam, M.D., Deputy Director, Center for Clinical Trials Network, National Institute on Drug Abuse, National Institutes of Health, Rockville, Maryland.
- Tison Thomas, M.S.W., Chief, State Grants Eastern Branch, Division of State and Community Systems Development, Center for Mental Health Services, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Christine Timko, Ph.D., Research Career Scientist, Health Services Research and Development, U.S. Department of Veterans Affairs, Menlo Park, California.
- Traci L. Toomey, Ph.D., Professor, Division of Epidemiology and Community Health, School of Public Health, University of Minnesota, Minneapolis, Minnesota.
- Paolo del Vecchio, M.S.W., Director, Center for Mental Health Services, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Mary Kate Weber, M.P.H, Behavioral Scientist, Division of Congenital and Developmental Disorders, National Center on Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Aaron White, Ph.D., Senior Advisor to the Director, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- William L. White, M.A., Emeritus Senior Research Consultant, Chestnut Health Systems, Bloomington, Illinois.
- Gary B. Wilcox, M.A., Ph.D., John A. Beck Centennial Professor in Communication, Moody College of Communication, Stan Richards School of Advertising and Public Relations, The University of Texas at Austin, Austin, Texas.
- David Wilson, Public Affairs Specialist, Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Ellen Witt, Ph.D., (retired) Deputy Director, Division of Neuroscience and Behavior, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Rockville, Maryland.
- Amy Funk Wolkin, Dr.P.H., M.S.P.H. , Chief, Health Studies Branch, Division of Environmental Hazards and Health Effects, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Albert M. Woodward, Ph.D., Chief, Analysis and Services Research Branch, Division of Evaluation, Analysis and Quality, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Marie Zeimetz, Ph.D., Writer-Editor, Office of the Director, Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Terry S. Zobeck, Ph.D., Associate Director, Office of Research/Data Analysis, Office of National Drug Control Policy, Executive Office of the President, Washington, D.C

## Other contributors were

- Deepa Avula, M.P.H., Director, Office of Financial Resources, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Amy Berninger, M.P.H., Senior Analyst, Abt Associates, Cambridge, Massachusetts.
- Margaret K. Gwaltney, M.B.A., Principal Associate, Abt Associates, Bethesda, Maryland.
- Kevin Hennessy, Ph.D., Former Deputy Director, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Janet Hightower, Digital Artist, Encinitas, California.
- Mariel J. McLeod, Research Assistant, Abt Associates, Bethesda, Maryland.
- Cori K. Sheedy, Ph.D., Senior Associate, Abt Associates, Cambridge, Massachusetts.
- Daniel J. Smith, Senior Graphic Designer, Abt Associates, Bethesda, Maryland.
- Alicia C. Sparks, Ph.D., Senior Analyst, Abt Associates, Bethesda, Maryland.
- Melanie Whitter, Principal Associate, Abt Associates, Bethesda, Maryland.