# CHAPTER 6 HEALTH CARE SYSTEMS AND SUBSTANCE USE DISORDERS

## Chapter 6 Preview

Services for the prevention and treatment of substance misuse and substance use disorders have traditionally been delivered separately from other mental health and general health care services. Because substance misuse has traditionally been seen as a social or criminal problem, prevention services were not typically considered a responsibility of health care systems^i^; and people needing care for substance use disorders have had access to only a limited range of treatment options that were generally not covered by insurance. Effective integration of prevention, treatment, and recovery services across health care systems is key to addressing substance misuse and its consequences and it represents the most promising way to improve access to and quality of treatment. Recent health care reform laws, as well as a wide range of other trends in the health care landscape, are facilitating greater integration to better serve individual and public health, reduce health disparities, and reduce costs to society.

KEY TERMS

Integration. The systematic coordination of general and behavioral health care. Integrating services for primary care, mental health, and substance use-related problems together produces the best outcomes and provides the most effective approach for supporting whole-person health and wellness.^3^

This chapter describes the key components of health care systems; historical reasons substance use and its consequences have been addressed separately from other health problems; the key role that health care systems can play in providing prevention, treatment, and recovery support services (RSS) for substance use disorders; and the recent developments that are leading to improved integration of substance use-related care with the rest of medicine. This chapter also describes the challenges to effective integration, as well as promising trends, such as in health information technology (health IT) that will facilitate it. Because these changes are still underway, much of the relevant research is still formative and descriptive; information presented in this chapter often derives from reports and descriptive papers.

KEY FINDINGS^*^ * The Centers for Disease Control and Prevention (CDC) summarizes strength of evidence as: “Well-supported”: when evidence is derived from multiple controlled trials or large-scale population studies; “Supported”: when evidence is derived from rigorous but fewer or smaller trials; and “Promising”: when evidence is derived from a practical or clinical sense and is widely practiced.^5^

- Well-supported scientific evidence shows that the traditional separation of substance use disorder treatment and mental health services from mainstream health care has created obstacles to successful care coordination. Efforts are needed to support integrating screening, assessments, interventions, use of medications, and care coordination between general health systems and specialty substance use disorder treatment programs or services.
- Supported scientific evidence indicates that closer integration of substance use-related services in mainstream health care systems will have value to both systems. Substance use disorders are medical conditions and their treatment has impacts on and is impacted by other mental and physical health conditions. Integration can help address health disparities, reduce health care costs for both patients and family members, and improve general health outcomes.
- Supported scientific evidence indicates that individuals with substance use disorders often access the health care system for reasons other than their substance use disorder. Many do not seek specialty treatment but they are over-represented in many general health care settings.
- Promising scientific evidence suggests that integrating care for substance use disorders into mainstream health care can increase the quality, effectiveness, and efficiency of health care. Many of the health home and chronic care model practices now used by mainstream health care to manage other diseases could be extended to include the management of substance use disorders.
- Insurance coverage for substance use disorder services is becoming more robust as a result of the Paul Wellstone and Pete Domenici Mental Health Parity and Addiction Equity Act (MHPAEA) and the Affordable Care Act. The Affordable Care Act also requires non-grandfathered individual and small group market plans to cover services to prevent and treat substance use disorders.
- Health care delivery organizations, such as health homes and accountable care organizations (ACOs), are being developed to better integrate care. The roles of existing care delivery organizations, such as community health centers, are also being expanded to meet the demands of integrated care for substance use disorder prevention, treatment, and recovery.
- Use of Health IT is expanding to support greater communication and collaboration among providers, fostering better integrated and collaborative care, while at the same time protecting patient privacy. It also has the potential for expanding access to care, extending the workforce, improving care coordination, reaching individuals who are resistant to engaging in traditional treatment settings, and providing outcomes and recovery monitoring.
- Supported evidence indicates that one fundamental way to address racial and ethnic disparities in health care is to increase the number of people who have health insurance coverage.
- Well-supported evidence shows that the current substance use disorder workforce does not have the capacity to meet the existing need for integrated health care, and the current general health care workforce is undertrained to deal with substance use-related problems. Health care now requires a new, larger, more diverse workforce with the skills to prevent, identify, and treat substance use disorders, providing “personalized care” through integrated care delivery.

## Key Components of Health Care Systems

In 2015, 20.8 million Americans had a substance use disorder. As discussed in Chapter 1 - Introduction and Overview, these disorders vary in intensity and may respond to different intensities of intervention. Diverse health care systems have many roles to play in addressing our nation's substance misuse and substance use disorder problems, including:

- Screening for substance misuse and substance use disorders;
- Delivering prevention interventions to prevent substance misuse and related health consequences;
- Early intervention to prevent escalation of misuse to a substance use disorder;
- Engaging patients with substance use disorders into treatment;
- Treating substance use disorders of all levels of severity;
- Coordinating care across both health care systems and social services systems including criminal justice, housing and employment support, and child welfare;
- Linking patients to RSS; and
- Long-term monitoring and follow-up.

There is a great diversity of health care systems across the United States, with varying levels of integration across health care settings and wide-ranging workforces that incorporate diverse structural and financing models and leverage different levels of technology.

### Health Care Settings

Health care systems are made up of diverse health care organizations ranging from primary care, specialty substance use disorder treatment (including residential and outpatient settings), mental health care, infectious disease clinics, school clinics, community health centers, hospitals, emergency departments, and others.

It is known that most people with substance use disorders do not seek treatment on their own, many because they do not believe they need it or they are not ready for it, and others because they are not aware that treatment exists or how to access it. But individuals with substance use disorders often do access the health care system for other reasons, including acute health problems like illness, injury, or overdose, as well as chronic health conditions such as HIV/AIDS, heart disease, or depression. Thus, screening for substance misuse and substance use disorders in diverse health care settings is the first step to identifying substance use problems and engaging patients in the appropriate level of care.

Mild substance use disorders may respond to brief counseling sessions in primary care, while severe substance use disorders are often chronic conditions requiring substance use disorder treatment like specialty residential or intensive outpatient treatment as well as long-term management through primary care. A wide range of health care settings is needed to effectively meet the diverse needs of patients.

### Workforce

Just as a diversity of health care settings is needed to meet the needs of patients, a diversity of health care professionals is also critical. Health care services can be delivered by a wide-range of providers including doctors, nurses, nurse practitioners, psychologists, licensed counselors, care managers, social workers, health educators, peer workers, and others. With limited resources for prevention and treatment, matching patients to the appropriate level of care, delivered by the appropriate level of provider, is crucial for extending those resources to reach the most patients possible.

### Structural and Financing Models

A range of promising health care structures and financing models are currently being explored for integrating general health care and substance use disorder treatment within health care systems, as well as integrating the substance use disorder treatment system with the overall health care system. As part of ongoing health reform efforts, both federal and state governments are investing in models and innovations ranging from health homes and ACOs, to managed care and Coordinated Care Organizations (CCOs), to pay-for-performance and shared-savings models. These new models are developing and testing strategies for effectively and sustainably financing high-quality care that integrates behavioral health and general health care.

FOR MORE ON THIS TOPIC

See the sections on “Health Homes” and “Accountable Care Organizations” later in this chapter.

### Technology Integration

Technology can play a key role in supporting these integrated care models. Electronic health records (EHRs), telehealth, health information exchanges (HIE), patient registries, mobile applications, Web-based tools, and other innovative technologies have the potential to extend the reach of the workforce; support quality measurement and improvement initiatives to drive a learning health care system; electronically deliver prevention, treatment, and recovery interventions; efficiently monitor patients; identify population health trends and threats; and engage patients who are hesitant to participate in formal care.

KEY TERMS

Learning Health Care System. As described by the Institute of Medicine (IOM), a learning health care system is “designed to generate and apply the best evidence for the collaborative healthcare choices of each patient and provider; to drive the process of discovery as a natural outgrowth of patient care; and to ensure innovation, quality, safety, and value in health care.”^4^

### The Promise of Integration

When health care is not well integrated and coordinated across systems, too many patients fall through the cracks, leading to missed opportunities for prevention or early intervention, ineffective referrals, incomplete treatment, high rates of hospital and emergency department readmissions, and individual tragedies that could have been prevented. For example, a recent study found that doctors continue to prescribe opioids for 91 percent of patients who suffered a non-fatal overdose, with 63 percent of those patients continuing to receive high doses; 17 percent of these patients overdosed again within 2 years.^6^ Effective coordination between emergency departments and primary care providers can help to prevent these tragedies.

Other tragedies occur when patients complete treatment and the health care system fails to provide adequate follow-up and coordination of the wrap-around services or recovery supports necessary to help them maintain their recovery, leading to relapse. The risk for overdose is particularly high after a period of abstinence, due to reduced tolerance—patients no longer know what a safe dose is for them—and this all too often results in overdose deaths. This is a common story when patients are released from prison without a coordinated plan for continuing treatment in the community. One study from the Washington State Department of Corrections found that during the first 2 weeks after release, the risk of death among former inmates was 12.7 times higher than among state residents of the same age, sex, and race. Health care systems play a key role in providing the coordination necessary to avert these tragic outcomes.^7^

KEY TERMS

Wrap-Around Services. Wrap-around services are non-clinical services that facilitate patient engagement and retention in treatment as well as their ongoing recovery. This can include services to address patient needs related to transportation, employment, childcare, housing, and legal and financial problems, among others.

## Substance Use Disorder Services Have Traditionally Been Separate From Mental Health and General Health Care

The separation of the treatment systems for substance use disorders, mental illness, and general health care has historical roots.^8-10^ For example, Alcoholics Anonymous (AA) was founded in 1935 in part because mainstream psychiatric and general medical providers did not attend to substance use disorders. If treated at all, alcoholism was most often treated in asylums, separate from the rest of health care. The separation of substance use disorder treatment and general health care was further influenced by social and political trends of the 1970s. At that time, substance misuse and addiction were generally viewed as social problems best dealt with through civil and criminal justice interventions such as involuntary commitment to psychiatric hospitals, prison-run “narcotic farms,” or other forms of confinement.^11^ However, when many college students and returning Vietnam veterans were misusing alcohol, using drugs, and/or becoming addicted to illicit substances, high numbers of arrests and other forms of punishment became politically and economically infeasible. At this time, there was a major push to significantly expand substance misuse prevention and treatment services.

Despite the compelling national need for treatment, the existing health care system was neither trained to care for, nor especially eager to accept, patients with substance use disorders. For these reasons, new substance use disorder treatment programs were created, ultimately expanding to programs in more than 14,000 locations across the United States. This meant that with the exception of withdrawal management in hospitals (detoxification), virtually all substance use disorder treatment was delivered by programs that were geographically, financially, culturally, and organizationally separate from mainstream health care.

FOR MORE ON THIS TOPIC

See Chapter 4 - Early Intervention, Treatment, and Management of Substance Use Disorders.

Even though these programs were separate from the rest of health care, these new delivery sites were a critical step toward better addressing the growing problems related to substance misuse and substance use disorders. One positive consequence was the initial development of effective and inexpensive behavioral change strategies rarely used in the treatment of other chronic illnesses. However, the separation of substance use disorder treatment from general health care also created unintended and enduring impediments to the quality and range of care options available to patients in both systems. For example, it tended to reinforce the notion that substance use disorders were different from other medical conditions. Despite numerous research studies documenting high prevalence rates of substance use disorders among patients in emergency departments, hospitals, and general medical care settings, mainstream health care generally failed to recognize or address substance use-related health problems.^8,12-15^

The continued separation of substance use and general health care services has been costly, often harmful, and for some individuals even fatal. A recent study of world health settings showed that the presence of a substance use disorder often doubles the odds that a person will develop another chronic and costly medical illness, such as arthritis, chronic pain, heart disease, stroke, hypertension, diabetes, or asthma.^16^ Yet despite the impact of substance use on physical health, few medical, nursing, dental, or pharmacy schools teach their students how to identify, prevent, and treat substance use disorders;^17-19^ and, until recently, few insurers offered comparable reimbursement for substance use disorder treatment services.^20-23^

KEY TERMS

Inpatient treatment. Intensive, 24-hour-a-day services delivered in a hospital setting.

Residential treatment. Intensive, 24-hour-a-day services delivered in settings other than a hospital.

Even now, there are health care professionals who continue to be hesitant to provide patients with medication-assisted treatment (MAT), especially maintenance medications (methadone and buprenorphine) for opioid use disorders, because of deeply ingrained but erroneous misconceptions about these treatments, such as the idea that they “substitute one addiction for another.”^24^ This has hindered the adoption of these effective medications even by substance use disorder treatment facilities; and when they are used by substance use disorder treatment providers, they are often prescribed at insufficient doses, for insufficient durations, contributing to treatment failure and reinforcing a belief that they are not effective.^25,26^ In fact, ample research shows that, when used correctly, MAT can reduce or eliminate illicit drug use and associated criminality and infectious disease transmission and restore patients to healthy functioning.^25,27,28^

## A Growing Impetus for Integration

An integrated system of prevention, early intervention, treatment, and recovery that can address the full spectrum of substance use-related health problems is a logical and necessary shift that our society must make to prevent substance misuse and its consequences and meet the needs of individuals with substance use disorders. Providing services to people with mild and moderate substance use disorders—by far the largest proportion of all those diagnosed—in general health care settings will likely lessen the need for intensive and costly substance use disorder treatment services later, even though specialty care is still essential for people with serious substance use disorders, just as it is for patients with other severe diseases and conditions.

FOR MORE ON THIS TOPIC

See Chapter 4 - Early Intervention, Treatment, and Management of Substance Use Disorders.

Beginning in the 1990s, a number of events converged to lay the foundation for integrated care. First, a number of IOM reports and other major articles established that substance use disorders are inherently health conditions that require a collaboration between general health care settings and specialty care^29^ to improve treatment^30^ and reduce gaps in quality for health care broadly^31^ and for mental disorders and substance use disorders in particular.^29,32^ This was followed, in more recent years, by legislation that aims to transform the way services are provided and to facilitate access to prevention and treatment services through expanded insurance coverage. The Paul Wellstone and Pete Domenici Mental Health Parity and Addiction Equity Act of 2008 (MHPAEA) requires the financial requirements and treatment limitations imposed by most health plans and insurers for substance use disorders be no more restrictive than the financial requirements and treatment limitations they impose for medical and surgical conditions.

Further, the Affordable Care Act, passed in 2010, requires that non-grandfathered health care plans offered in the individual and small group markets both inside and outside insurance exchanges provide coverage for a comprehensive list of 10 categories of items and services, known as “essential health benefits.” One of these essential health benefit categories is mental health and substance use disorder services, including behavioral health treatment. This requirement represents a significant change in the way many health insurers respond to these disorders. The Affordable Care Act also reaffirmed MHPAEA by requiring that mental health and substance use disorder benefits covered by plans offered through the exchanges be offered consistent with the parity requirements under MHPAEA.

Medicaid Expansion under the Affordable Care Act

To more broadly cover uninsured individuals, the Affordable Care Act includes a provision that allows states to expand Medicaid coverage. In those states (“Medicaid expansion states”), individuals in households with incomes below 138 percent of the federal poverty level are eligible for Medicaid. Benefits include mental health and substance use disorder treatment services with coverage equivalent to that of general health care services.

Medicaid expansion is a key lever for expanding access to substance use treatment because many of the most vulnerable individuals with substance use disorders have incomes below 138 percent of the federal poverty level. As of fall 2015, an estimated 3 million adults have incomes that make them eligible for Medicaid under the Affordable Care Act but live in a state that has declined to expand Medicaid eligibility as permitted under the new law.^36,37^

A major goal of the Affordable Care Act is to expand insurance coverage and reduce the number of uninsured individuals.^33^ As of March 2016, more than 20 million previously uninsured individuals (including children on parents' plans) had new benefits under the Affordable Care Act.^34^ These enrollment figures include those who were previously uninsured, as well as 1 million who previously had employer-based coverage and 3 million who previously had non-group and other insurance coverage.^33^ Individuals with substance use disorders are overrepresented in the newly insured population (including children now on parents' plans), because they were previously disproportionately uninsured, young adults without dependent children. They now are eligible for coverage under the Affordable Care Act, which will enable them to receive substance use disorder prevention, treatment, and RSS.^35^

Most recently, Congress passed the Protecting Access to Medicare Act, which, in addition to its Medicare provisions, funds pilot programs to increase access to, and Medicaid payment for, community mental health and substance use disorder treatment services. This is an important opportunity for integration.

Other changes, described later in this chapter, are also helping to create momentum for integration. These include new or improved organizational structures, such as medical homes, health homes, and ACOs; improved health IT, such as EHRs; clinical approaches, such as new substance use disorder treatment medications that can be prescribed in primary care settings; and effective approaches to identifying and preventing substance misuse problems. In addition, organizations including the American College of Physicians and the American Society of Addiction Medicine (ASAM) now recommend integration of substance use-related and mental health services with primary care.^38^ Of historical note, although the World Health Organization and the American Medical Association have long identified alcohol and drug use disorders as medical conditions, it was only in 2016 that addiction medicine was formally recognized as a new subspecialty by the American Board of Medical Specialties under the American Board of Preventive Medicine.

Figure 6.1 summarizes a few of the key changes that are occurring as substance use disorder treatment services are integrated into mainstream health care.

Figure 6.1 Substance Use Disorders Services: Past and Future

Past | Future
Substance use mainly ignored in primary care | Substance use screened and monitored in primary care
Focus on the most severe problems | Addresses full spectrum of problems
Paper charts: little contact between specialty substance use disorders and health care | EHR, clinical coordination, patient portals, health IT treatment options that focus on coordination of care
Limited use of health IT | Leveraging technologies including patient portals, HIEs, technology delivered treatments
Little focus on physical health issues | Addresses medical problems with focus on whole person wellness
Medications seldom available | Medications readily available
Separate oversight structures and reporting | Performance and outcomes measurement, ongoing quality improvement
12-step programs | 12-step and other RSS, social network innovations

Health care professionals are being encouraged to offer prevention advice, screen patients for substance misuse and substance use disorders, and provide early interventions in the form of motivational approaches, when appropriate.^39,40^

Primary care has a central role in this process, because it is the site for most preventive and ongoing clinical care for patients—the patient's anchor in the health care system. For example, primary care settings can serve as a conduit to help patients engage in and maintain recovery. Also, approaches such as screening, brief intervention, and referral to treatment (SBIRT) provide primary care providers with tools for addressing patients' substance misuse. Based upon the strength of the evidence for their effectiveness, the U.S. Preventive Services Task Force (USPSTF) has recommended alcohol screening and brief behavioral counseling interventions for adults in primary care and given the supporting evidence for these services a “B” grade. This is significant because under the Affordable Care Act, preventive services given a grade of A or B by the USPSTF must be covered by most health plans without cost-sharing.^41-43^ The USPSTF recommendation supports the expectation that primary care providers will soon routinely screen adults of all ages for unhealthy alcohol use as they now do for blood pressure and weight. Relatedly, the National Commission on Prevention Priorities of the Partnership for Prevention ranks primary care-based interventions to reduce alcohol misuse among the most valuable clinical preventive services.^44,45^

FOR MORE ON THIS TOPIC

See Chapter 4 - Early Intervention, Treatment, and Management of Substance Use Disorders.

The literature on the effectiveness of drug-focused brief intervention in primary care and emergency departments is less clear, with some studies finding no improvements among those receiving brief interventions.^46,47^ However, at least one study found significant reductions in subsequent drug use.^48^ Trials evaluating different types of screening and brief interventions for drug use in diverse settings with a range of patient groups are lacking. The USPSTF's current rating for illicit drug screening and brief intervention remains “I” for insufficient evidence to support its use as a preventive service. However, assessment for drug use is recommended under numerous circumstances, including treating any condition for which drug use might interfere with the treatment; considering potential interactions with prescribed medications; supporting integration of behavioral health care; and monitoring patient risk when prescribing opioid pain medications or sedatives/tranquilizers.

It is also important to emphasize that brief primary care-based interventions by themselves are likely not sufficient to address severe substance use disorders. However, primary care providers can use other interventions with this population, including providing MAT, providing more robust monitoring and patient education,^49,50^ and importantly, referring individuals to specialty substance use disorder treatment. Effective referral arrangements that include motivating patients to accept the referral are critical elements to encourage individuals to engage in treatment for their substance use disorder.

### Reasons Why Integrating Substance Use Disorder Services and Mainstream Health Care Is Necessary

A number of strong arguments underpin the growing momentum to integrate substance use disorder services and mainstream health care. The main argument is that substance use disorders are medical conditions like any other—the overarching theme of much of this Report. Recognition of that fact means it no longer makes sense to keep substance use disorders segregated from other health issues. A number of other realities support the need for integration:^63^

- Substance use, mental disorders, and other general medical conditions are often interconnected;
- Integration has the potential to reduce health disparities;
- Delivering substance use disorder services in mainstream health care can be cost-effective and may reduce intake/treatment wait times at substance use disorder treatment facilities; and
- Integration can lead to improved health outcomes through better care coordination.

Health Systems and Opioids

Physician prescribing patterns, patient drug diversion (selling, sharing, or using medications prescribed for another person), and doctor shopping behaviors have all contributed to the ongoing opioid overdose epidemic.^51^ For example, evidence indicates that chronic pain patients with substance use disorders are prescribed opioids more often than other individuals with chronic pain, with the trend increasing over time.^52^ Also, a study in two health systems found opioid prescription rates for older persons, particularly older women,^53^ to be higher over time than for other individuals with long-term chronic pain.

In March 2015, the U.S. Department of Health and Human Services (HHS) made addressing the opioid misuse crisis a high priority, announcing a national opioid initiative focused on three priority areas: (1) providing training and educational resources, including updated prescriber guidelines, to assist health professionals in making informed prescribing decisions; (2) increasing use of the opioid overdose reversal drug naloxone; and (3) expanding the use of MAT. Since then, HHS has initiated many efforts to help reduce prescription opioid misuse and use disorders. Improving prescribing practices is one of these important efforts.^54^ In March 2016, the CDC released the Guideline for Prescribing Opioids for Chronic Pain, which provides recommendations about the appropriate prescribing of opioid pain relievers and other treatment options to improve pain management and patient safety.^55^ The guideline is not intended to regulate necessary and appropriate opioid prescribing. Rather, the guideline is meant to inform health care professionals about some of the consequences of treatment with opioids for chronic pain and to consider, when appropriate, tapering and changing prescribing practices, as well as considering alternative pain therapies. The same month, HHS also released the National Pain Strategy, which outlines the federal government's first coordinated plan for addressing chronic pain that affects so many Americans.^56^ The goals of the National Pain Strategy will be achieved through a broad effort that includes improved pain care and safer prescribing practices, such as those recommended by the CDC Guideline.

The National Heroin Task Force, which consisted of law enforcement, doctors, public health officials, and education experts, was convened to develop strategies to confront the heroin problem and decrease the escalating overdose epidemic and death rate.^57^ In 2015, the Task Force developed a report outlining the steps being taking to address the opioid problem. This included a multifaceted strategy of enforcement and prevention efforts, as well as increased access to substance use disorder treatment and recovery services. Although only about 4 percent of those who misuse prescription opioids transition to using heroin, concern is growing that tightening restrictions on opioid prescribing could potentially have unintended consequences resulting in new populations using heroin.^58^ The Task Force states that “evidence shows that some people who misuse opioid medications migrate to heroin because heroin is more accessible and less costly than prescription opioids.”^59^ In fact, nearly 80 percent of recent heroin initiates reported that they began their opioid use through the nonmedical use of prescription opioid medications.”^58^

The concern about opioid overdoses has also triggered efforts by health systems to increase access to naloxone, an opioid antagonist that prevents overdose fatalities by rapidly restoring normal respiration to a person whose breathing has slowed or stopped as a result of opioid use. Since 1996, community-based organizations in many states have implemented overdose education and naloxone distribution programs for people who use heroin or misuse pharmaceutical opioids and efforts are underway to expand access to naloxone to patients who are prescribed opioids for pain. Expanded access to naloxone through large health systems could prevent overdose fatalities in broad populations of patients, including patients who may experience accidental overdose from misusing their medications. The Substance Abuse and Mental Health Services Administration (SAMHSA) has developed an easy-to-use toolkit to be distributed with naloxone.^60^ Prior research has suggested the potential to translate overdose education and naloxone distribution into routine primary care practice^61^ and examination of the perspectives of primary care providers on this practice revealed knowledge gaps about naloxone but also a willingness to follow standardized naloxone prescribing practices when they emerge.^62^

FOR MORE ON THIS TOPIC

See Chapter 4 - Early Intervention, Treatment, and Management of Substance Use Disorders.

#### Substance Use Disorders, Mental Disorders, and Other Medical Conditions Are Interconnected

Many individuals who come to mainstream health care settings, such as primary care, obstetrics and gynecology, emergency departments, and hospitals, also have a substance use disorder. In a study within one health plan, one third of the most common and costly medical conditions were markedly more prevalent among patients with substance use disorders than they were among similar health system members who did not have a substance use disorder.^64^ Similarly, many individuals who present at specialty substance use disorder treatment programs have other medical conditions,^65,66^ including hypertension, HIV/AIDS, coronary artery disease, hepatitis, chronic liver disease, and psychiatric disorders.^67^

Because substance use complicates many other medical conditions, early identification and management of substance misuse or use disorders presents an important opportunity to improve health outcomes and reduce health care costs.^68^ Research shows that primary care patients with mild or moderate substance use have higher rates of other medical problems, including injury, hypertension, and psychiatric disorders, as well as higher costs.^69^ For example, cocaine use is associated with cardiovascular complications^67,70,71^ and neurological and psychiatric disorders,^67,71^ and long-term marijuana use has been associated with chronic bronchitis and cardiovascular problems.^72-74^ Alcohol misuse is associated with liver and pancreatic diseases; hypertension; reproductive system disorders; trauma; stroke;^75^ and cancers of the oral cavity, esophagus, larynx, pharynx, liver, colon, and rectum.^76,77^ Even one drink per day may increase the risk of breast cancer. ^67,76,78^

In addition to the health problems faced by individuals engaged in substance use mentioned above, substance use can adversely affect a developing fetus. In the United States, fetal alcohol spectrum disorders (FASD) remain highly prevalent and problematic, even though they are preventable.^79^ A study of children in public and private schools in a Midwestern community calculated rates of FASD to be as high as 6 to 9 per 1,000.^80^

Opioid pain reliever use among pregnant women has also become a major concern due to neonatal abstinence syndrome (NAS), a treatable condition that newborns experience after exposure to drugs while in the mother's womb.^81^ NAS may cause neurological excitability, gastrointestinal dysfunction, and autonomic dysfunction. Newborns with NAS are more likely than other babies to also have low birthweight and respiratory complications. The incidence of NAS has increased dramatically in the last decade along with increased opioid misuse.^82^ In 2012, an estimated 21,732 infants were born with NAS, a five-fold increase since 2000. Moreover, in 2012, newborns with NAS stayed in the hospital an average of 16.9 days, more than eight times the number of days other newborns stay in the hospital (2.1 days).^83^ These newborns with NAS cost hospitals an estimated $ 1.5 billion, and 81 percent of these costs were paid by state Medicaid programs.^83^ These data suggest the need to develop and test measures to reduce newborn exposure to opioids. For women who are considering getting pregnant or are already pregnant, abstaining from all substances is recommended, since NAS is not exclusively caused by opioids.^84^

Adolescents with substance use disorders experience higher rates of other physical and mental illnesses, as well as diminished overall health and well-being.^85-88^ Sexually transmitted infections and HIV/AIDS,^89^ appetite changes and weight loss, dermatological problems, gastrointestinal problems, headaches,^86^ insomnia and chronic fatigue,^90^ and heart, lung, and abdominal abnormalities are only some of the problems that affect the health of young people who misuse alcohol and drugs.^87^ A study of adolescents entering specialty substance use disorder treatment—as compared with age-matched adolescent patients without a substance use disorder—found higher rates of clinically diagnosed sinusitis, asthma, abdominal pain, sleep disorders, injuries and overdoses.^91^

In addition to the physical health problems described above, mental health problems are also over-represented among adolescents with substance use disorders,^92,93^ particularly attention-deficit hyperactivity disorder,^94-98^ conduct disorders,^99^ anxiety disorders,^100^ and mood disorders.^101-103^ In addition, alcohol and drug use are associated with serious personal and social problems for users and for those around them including elevated rates of morbidity and mortality related to traffic crashes, intimate partner violence, risky sex, and unintentional injuries, including death from overdose.^104-110^

FOR MORE ON THIS TOPIC

See Chapter 1 - Introduction and Overview.

#### Integration Can Lead to Improved Health Outcomes through Better Care Coordination

Treatment of substance use disorders has historically been provided episodically, when a person experiences a crisis or a relapse occurs.^32^ This is neither good quality nor efficient care, because severe substance use disorders are chronic health problems, similar to other health conditions and with similar outcomes.^12,111^ Studies conducted over extended periods of time have found that annual primary care visits were associated with better outcomes and reduced health care costs following substance use disorder treatment,^112-115^ but research on models of chronic care management is only beginning and thus far no consensus has emerged on the best approach.^116-119^ These types of long-term studies will be more informative as the substance use disorder treatment, health care, and mental health systems become more integrated and as researchers build on disease management models that are effective for other medical conditions.

In addition to chronic care management for severely affected individuals, coordinating services for those with mild or moderate problems is also important. Studies of various methods for integrating substance use services and general medical care have typically shown beneficial outcomes.^66,120,121^ The effectiveness of providing alcohol screening and brief counseling in primary care is supported by a robust evidence base,^122^ and a growing literature is showing its benefits as a first tool in managing chronic health conditions that may arise from, or be exacerbated by, alcohol use.^123-125^ Primary care-based alcohol use disorder case management involving pharmacotherapy and psychosocial support has been found to increase engagement in specialty substance use disorder treatment and to decrease heavy drinking.^126^

Care coordination is an essential part of quality in all health care. The Healthcare Effectiveness Data and Information Set (HEDIS), The Joint Commission, and organizations such as the National Committee for Quality Assurance emphasize coordination and accountability and the use of evidence-based care and performance indicators to establish and monitor quality and value. This approach to care delivery proceeds on the assumption that services for the range of substance use disorders should be fully integrated components of mainstream health care.

Quality and Performance Measurement and Accountability

Publicly available quality measurement information helps consumers, health care purchasers, and other groups make informed decisions when choosing services, providers, and care settings. Performance measurement has the dual purpose of accountability and quality improvement.

A 2015 IOM study on Psychosocial Interventions for Mental and Substance Use Disorders recommended that the substance use disorder field develop approaches to measure quality, similar to approaches used for other diseases. This includes the development of performance measures, use of health IT for standardized measurement, and utilization of these measures to support quality improvement.^127^

Measures have been proposed by a variety of organizations, including SAMHSA, as part of its 2013 National Behavioral Health Quality Framework; by the ASAM, as part of its development of standards of care for specialist addiction medicine physicians; by the Behavioral Health Steering Committee of the National Quality Forum; and by accrediting bodies such as The Joint Commission. Many measures are being tested by public and private health plans, though most have not been adopted widely for quality improvement and accountability. The single substance use measure included in HEDIS is “initiation and engagement of alcohol and other drug dependence treatment.” Although the HEDIS measure is limited, it does provide health systems a beginning benchmark for tracking substance use disorders. A measure of care continuity after emergency department use for substance use disorders is in process.

Because substance use disorder treatment is currently not well integrated and services are often provided by multiple systems, it can be challenging to effectively measure treatment quality and related outcomes. The ability to track service delivery across these multiple environments will be critical for addressing this challenge. For example, community monitoring systems to assess risk and protection for adolescents are being developed.^128-130^

Pay-for-performance is an approach for improving quality and for incentivizing programs or health care professionals to produce particular outcomes (for example, treatment retention and treatment outcomes). It has been used more in general health care than in substance use disorder treatment. However, Delaware and Maine have experimented with it in their public substance use disorder treatment systems, and several studies have found improvement in retention and outcomes.^131,132^ Potential concerns with pay-for-performance are that treatment programs may not accept the most severe patients and that methods of risk adjustment to compensate programs that accept those patients are not well-established. Although pay-for-performance is a promising approach, more research is needed to address these concerns.

A fundamental concept in care coordination between the health care, substance use disorder treatment, and mental health systems is that there should be “no wrong door.”^133^ This means that no matter where in the health care system the need for substance use disorder treatment is identified the patient will be effectively linked with appropriate services.

Several models of coordination have been described by researchers. In one such model, coordination ranges from referral agreements to co-located substance use disorder, mental health, and other health care services. Onsite programs had the highest rates of treatment engagement.^134^ A recent meta-analysis concluded that integrated treatment of adolescent substance use disorders, along with mental disorders and medical care, produced better outcomes than when treatment was provided separately.^135^ Other observational research has found that co-location of specialty substance use disorder treatment and mental health care is associated with better outcomes in adolescents.^93^ SAMHSA and the Health Resources and Services Administration (HRSA) have also developed a model with six levels of coordination (Figure 6.2).

Figure 6.2 A Continuum of Collaboration between Health Care and Specialty Services

Coordinated Key Element: Communication | | Co-located Key Element: Physical Proximity | | Integrated Key Element: Practice Change
LEVEL 1 | LEVEL 2 | LEVEL 3 | LEVEL 4 | LEVEL 5 | LEVEL 6
Minimal Collaboration | Basic Collaboration at a Distance | Basic Collaboration Onsite | Close Collaboration Onsite with Some System Integration | Close Collaboration Approaching an Integrated Practice | Full Collaboration in a Transformed/Merged Integrated Practice
Behavioral health, primary care, and other health care professionals work:
In separate facilities, where they: | In separate facilities, where they: | In same facility not necessarily same offices, where they: | In same space within the same facility, where they: | In same space within the same facility (some shared space), where they: | In same space within the same facility, sharing all practice space, where they:
- Have separate systems; - Communicate about cases only rarely and under compelling circumstances; - Communicate, driven by provider need; - May never meet in person; - Have limited understanding of each other's roles | - Have separate systems; - Communicate periodically about shared patients; - Communicate, driven by specific patient issues; - May meet as part of a larger community; - Appreciate each other's roles as resources | - Have separate systems; - Communicate regularly about shared patients, by phone or e-mail; - Collaborate, driven by need for each other's services and more reliable referral; - Meet occasionally to discuss cases due to close proximity; - Feel part of a larger yet non-formal team | - Share some systems, like scheduling or medical records; - Communicate in person as needed; - Collaborate, driven by need for consultation and coordinated plans for difficult patients; - Have regular face-to-face interactions about some patients; - Have a basic understanding of roles and culture | - Actively seek system solutions together or develop work-a-rounds; - Communicate frequently in person; - Collaborate, driven by desire to be a member of the care team; - Have regular team meetings to discuss overall patient care and specific patient issues; - Have an in-depth understanding of roles and culture | - Have resolved most or all system issues, functioning as one integrated system; - Communicate consistently at the system, team, and individual levels; - Collaborate, driven by shared concept of team care; - Have formal and informal meetings to support integrated model of care; - Have roles and cultures that blur or blend

Source: Heath, et al., (2013).^136^

These models, as well as recovery-oriented systems of care, provide opportunities for substance use disorder services and mainstream health care to engage in various types of collaborative efforts to integrate their services at all stages: prevention, treatment, and recovery. Importantly, the models all emphasize the relationship between person-centered, high-quality care and fully integrated models. Innovative financing mechanisms now being explored also allow for formal arrangements to implement some of the models discussed above, including linking to off-site health professionals in specialty substance use disorder treatment settings (and vice versa) when locating multiple services at one site is not feasible.

#### Integration Can Help Address Health Disparities

Integrating substance use services with general health care (e.g., in community health centers) provides opportunities to address longstanding health disparities. Prevalence of substance misuse and substance use disorders differs by race and ethnicity, sex, age, sexual orientation, gender identity, and disability, and these factors are also associated with differing rates of access to both health care and substance use disorder treatment. These differences are often exacerbated by socioeconomic variables.^137,138^ Some racial and ethnic groups experience disparities in entering and engaging in treatment. A study of a large health system found that Black or African American women but not Latina or Asian American women were less likely to attend substance use disorder treatment, after controlling for other factors; there were no ethnicity differences for men.^139^

In addition, an analysis of longitudinal data from the National Epidemiologic Survey on Alcohol and Related Conditions showed that individuals from most racial and ethnic groups were less likely to receive an alcohol intervention than were White individuals over a 3 year period.^140^ Controlling for socioeconomic status and clinical conditions increased the disparity, and Hispanic or Latino individuals were the least likely to receive services. Differences within the various racial and ethnic groups by sex were not studied.

A fundamental way to address disparities is to increase the number of people who have health coverage. The Affordable Care Act provides several mechanisms that broaden access to coverage. As a result, more low-income individuals with substance use disorders have gained health coverage, changed their perceptions about being able to obtain treatment services if needed, and increased their access to treatment.^141^ However, in states that have elected not to expand Medicaid, some low-income adults who need substance use disorder treatment, especially single childless adults, are unable to receive these services. Individuals whose incomes are too high to qualify for Medicaid but are not high enough to be eligible for qualified health plan premium tax credits also rarely have coverage for substance use disorder treatment.^142^ As Figure 6.3 shows, more Blacks or African Americans are in the coverage gap than other groups, and more Hispanics or Latinos are ineligible due to immigration status.^142^ One study conducted by The Pew Charitable Trusts reported that 14 percent of the low-income adults who are newly eligible for Medicaid under the Affordable Care Act have drug and alcohol addictions, compared to 10 percent in the general population. Because the new Medicaid population includes large numbers of young, single men—a group at much higher risk for alcohol and drug misuse—Medicaid enrollees needing treatment could more than double, from 1.5 million prior to the 2014 Medicaid expansion to about 4 million in the next five years.^8,143,144^

Figure 6.3 Eligibility for Affordable Care Act Coverage Among the Nonelderly Uninsured by Race and Ethnicity, as of 2015

Notes: Totals may not sum to 100 percent due to rounding. Ineligible for Financial Assistance share includes those ineligible due to offer of employer sponsored insurance or income. Tax Credit Eligible share includes adults in MN and NY who are eligible for coverage through the Basic Health Plan.

Source: Kaiser Family Foundation analysis based on 2015 Medicaid eligibility levels and 2015 Current Population Survey.^142^

Bar graph shows percent of nonelderly uninsured individuals eligible for Affordable Care Act coverage by race and ethnicity as of 2015. The sample size included 14.5 million Whites, 4.5 million Blacks, and 10.9 million Hispanics. The graph shows the following: - 36% of Whites, 23% of Blacks and 16% of Hispanics were ineligible for financial assistance. - 2% of Whites, 4% of Blacks, and 37% of Hispanics were ineligible due to immigration status. - 9% of Whites, 21% of Blacks, and 6& of Hispanics were in the coverage gap. - 27% of Whites, 23% of Blacks, and 16% of Hispanics were eligible for tax credits. - 8% of Whites, 10% of Blacks, and 11% of Hispanics were Medicaid eligible children. - 18% of Whites, 19% of Blacks, and 14% of Hispanics were Medicaid eligible adults.

Another way to address disparities is to ensure that substance misuse prevention, interventions, treatments, and recovery services are tailored and relevant to the populations receiving them. Several interventions have been adapted explicitly to address differences in specific populations; they were either conducted within health care settings or are implementable in those settings. The list below provides examples of such programs that have been shown to be effective in diverse populations:

- An evidence-based prevention intervention focused on women who are at risk for an alcohol-exposed pregnancy because of risky drinking and not using contraception consistently and correctly.^145^ The program has been adapted to serve American Indian women of the Oglala Sioux Tribe.^146^ Implementation of this intervention in health care settings has high potential for improving outcomes.
- A study of a computerized screening and brief intervention in both Spanish and English used in a public health center's obstetrics-gynecology department was shown to be feasible and accepted by patients.^147^
- A small trial of Latino heavy drinkers compared culturally adapted motivational interviewing to motivational interviewing that was not culturally adapted. The trial suggested stronger results for the culturally adapted program.^148^
- A study comparing rural and urban differences in screening for substance use disorders in mental health clinics did not find significant differences in screening outcomes. However, rural clinics did significantly less following up for substance use problems in their patients than their urban counterparts. Larger rural clinics did better than small ones.^149^

FOR MORE ON THIS TOPIC

See Chapter 3 - Prevention Programs and Policies and Chapter 4 - Early Intervention, Treatment, and Management of Substance Use Disorders.

Importantly if health care systems systematically screen to identify individuals with risky use or potential substance use disorders, and respond appropriately to the level of the identified problem (with brief interventions, medications, and/or referral to specialty substance use disorder treatment), disparities in the use of treatment among those populations should lessen dramatically. In other words, it is expected that the number of people who seek treatment across all racial and ethnic groups will increase.

Few studies have directly compared treatment populations by race and ethnicity. However, some studies have examined race and ethnicity as predictors of outcomes in analyses controlling for many other factors (such as age, substance use disorder severity, mental health severity, social supports), and they showed that after accounting for these socioeconomic factors, outcomes did not differ by race and ethnicity. Some examples from an integrated health system include adolescent studies comparing Blacks or African Americans, American Indians or Alaska Natives, Hispanics or Latinos, and Whites.^150-152^ The same is true for short-term and long-term treatment outcomes of adults.^112,153-155^

This body of research has some key caveats. For example, studies have found that matching programs and providers by race or ethnicity may produce better results for Hispanics or Latinos than for other racial and ethnic groups.^156^ However, this research also suggests that all racial and ethnic groups can benefit equally from substance use disorder treatment. At the same time, offering programs that are tailored to patient characteristics or that incorporate health care professionals who share similarities with their patients in sex, age, or race or ethnicity may improve willingness to enter and engage in treatment.^157-159^

FOR MORE ON THIS TOPIC

See the section on “Considerations for Specific Populations” in Chapter 4 - Early Intervention, Treatment, and Management of Substance Use Disorders.

It should also be noted that civil rights laws, such as Section 504 of the Rehabilitation Act, the Americans with Disabilities Act (ADA), and Section 1557 of the Affordable Care Act, protect many people with substance use disorders and impose requirements on substance use disorder treatment programs. These laws require individual assessment of a person with a disability, identifying and implementing needed reasonable modifications of policies and practices when necessary to provide an equal opportunity for a person with a disability to participate in and benefit from treatment programs. More generally, these laws prohibit programs from excluding individuals from treatment programs on the basis of a co-occurring disability, if the individual meets the qualifications for the program. Additionally, under Title VI of the Civil Rights Act and Section 1557 of the Affordable Care Act, providers who receive federal financial assistance must address the needs of people with limited English proficiency. The ADA and Section 504 also apply to discriminatory zoning laws and decisions that operate as a barrier to providers seeking to open or expand substance use disorder treatment programs.^160^

As the section on Electronic Health Records and Health Information Technology shows, health IT holds tremendous promise to provide culturally appropriate services in multiple languages and that incorporate health care professionals with characteristics similar to the target patients' population. One example with cultural relevance is a pilot randomized trial of a computer-delivered brief intervention in a prenatal clinic, which matched health care professionals and patients on race/ethnicity; patients found the intervention to be easy to use and helpful.^161^ Such services have the potential to be cost-effective and to reach individuals in rural or urban settings and those who have difficulty attending treatment, including those with disabilities.

#### Integration Can Reduce Costs of Delivering Substance Use Services

With scarce resources and many social programs competing for limited funding, cost-effectiveness is a critical aspect of substance use-related services. Over the past 20 years, several comprehensive literature reviews have examined the economics of substance use disorder treatment.^162-165^

Although the United States spends roughly $35 billion across public and private payors to treat substance use disorders,^166,167^ the social and economic costs associated with these disorders are many times higher: Annual costs of substance misuse and substance use disorders in the United States are estimated at more than $400 billion.^168,169^ Thus, treating substance use disorders has the potential for positive net economic benefits, not just in regard to treatment services but also general health care.^162,170-172^ For example, on average individuals with chronic medical conditions incur health care costs two to three times higher when they have a comorbid substance use disorder compared with individuals without this comorbidity.^173^ The net benefits of integrated treatment include improved health care outcomes and reduced health care costs, as well as reduced crime, improved child welfare, and greater employment productivity.^125,174-178^ Major individual and societal savings also stem from fewer interpersonal conflicts, greater workplace productivity, reduced infectious disease transmission, and fewer drug-related accidents, including overdoses and deaths.^179^

KEY TERMS

Net economic benefit. The value of total benefits minus total costs.

Evaluations of Medicaid expenditures for substance use disorder treatment show that the costs of treating substance use disorders are more than offset by the accompanying savings to Medicaid in reduced health care costs, such as reductions in future substance use disorder-related hospitalizations and residential treatment costs.^188-190^ For example, as discussed below, an analysis of Washington State Medicaid found that providing substance use disorder treatment resulted in aggregate net savings to the Medicaid program, in the millions of dollars.^190^ These and other studies point out that investments in engaging people into effective treatment for substance use disorders will reduce costs in many areas.

Costs of Substance Use Disorders in Other Service Systems

Costs associated with substance use disorders are not limited to health care. The accumulated costs to the individual, the family, and the community are staggering and arise as a consequence of many direct and indirect effects, including compromised physical and mental health, loss of productivity, reduced quality of life, increased crime and violence, misuse and neglect of children, and health care costs.

###### Criminal Justice System

As described elsewhere in this Report, a substance use disorder is a substantial risk factor for committing a criminal offense. Reduced crime is thus a key component of the net benefits associated with prevention and treatment interventions. Overall, within the criminal justice system, more than two thirds of jail detainees and half of prison inmates experience substance use disorders.^180,181^ Many require treatment interventions, although only approximately 10 percent of prison inmates receive substance use disorder treatment services.^181^ Applying inflation-adjusted estimates of the costs of in-prison care, the public sector spends approximately $400 million on such prison-based services, with substantial additional costs for after-care.^182^

###### Child Welfare and Related Service Systems

Substance use-related costs are also prominent within child welfare and related services. The estimated prevalence of substance use disorders among parents involved in the child welfare system varies across service populations, time, and place. One widely cited estimate is that between one-third and two-thirds of parents involved with the child welfare system experience some form of substance use problem.^183^

The National Survey of Child and Adolescent Weil-Being found that caseworkers perceived substance misuse problems in 23 percent of cases, which was correlated with significantly higher probabilities of severe harm to children (24 percent), compared with parents with no such indication (5 percent).^184^ Consistent with these findings, caseworker-perceived substance misuse problems were associated with more than twice the risk of out-of-home, or foster care, placement (38 percent vs. 16 percent) within this sample. Children of parents with substance use problems were more likely than others to require child protective services at younger ages, to experience repeated neglect and abuse from parents, and to otherwise require more intensive and intrusive services.^183^ An estimated 19 percent of adolescents served by the child welfare system have experienced some substance use disorder, highlighting another challenge facing these service systems.^185^

In fiscal year 2016, approximately $5.2 billion was proposed for Federal Title IV-B, IV-E, and child abuse prevention services. Substance use disorders appear to account for a large proportion of child welfare, foster care, and related expenditures in the United States.

###### Military Health System

The United States military health system includes Department of Defense (DoD), Army, Navy, Air Force, and Marine Corps programs as well as health care outside the direct care system (TRICARE) for military members and their dependents, both in the United States and abroad. It is one of the largest health care systems in the United States. The IOM conducted a comprehensive study of military prevention and treatment services for substance use disorders.^186^ As found in other health systems discussed in this Report, the prevalence of alcohol problems is high. A study of the economic impact of alcohol misuse among beneficiaries of the DoD's TRICARE insurance program found that the DoD spent approximately $1.2 billion to address problems related to alcohol use in 2006: $425 million in medical costs and $745 million in reduced readiness and misconduct.^187^ In addition, opioid use disorders, often initiated when opioids are prescribed following injuries during deployment, are increasing at a high rate and are of high concern. Further, service members and veterans suffer from high rates of co-occurring health problems that pose significant treatment challenges, including traumatic brain injury, post-traumatic stress disorder, depression, and anxiety. Along with other recommendations, the IOM report recommended conducting routine screening, integrating substance use treatment with other health care, and implementing evidence-based treatments.

These illustrative examples underscore that the costs associated with substance use disorders are incurred across diverse service systems that serve vulnerable populations. These expenditures might be reduced through more aggressive measures to address substance misuse problems and accompanying disorders. Moreover, many substance use-related services provided through criminal justice, child welfare, or other systems seek to ameliorate serious harms that have already occurred, and that might have been prevented with greater impact or cost-effectiveness through the delivery of evidence-based prevention or early treatment interventions.

#### Economic Analyses can Assess the Value of Substance Use Interventions

Different kinds of economic analyses can be particularly useful in helping health care systems, community leaders, and policymakers identify programs or policies that will bring the greatest value for addressing their needs. Two commonly used types of analyses are cost-effectiveness analysis^199^ and cost-benefit analysis. Both types of studies have been used to examine substance use disorder treatment and prevention programs. Studies have found a number of substance use disorder treatments, including outpatient methadone, alcohol use disorder medications, and buprenorphine, to be cost-effective compared with no treatment.^162,200-209^ The same is true for outpatient services without MAT and residential levels of treatment.

##### Cost-effectiveness Analyses

Treatment Settings and Approaches. A 2003 study estimating the cost-effectiveness of four different treatment modalities—inpatient, residential, outpatient methadone, and outpatient without MAT—found that the treatment of substance use disorders is cost-effective compared to other health interventions, with outpatient programs without MAT being the most cost-effective. Estimated cost per abstinent case ranged from $11,411 for outpatient treatment without MAT to $28,256 in the inpatient setting, with an average cost across all modalities of $22,460 per abstinent study participant (adjusted to 2014 dollars).^205^

Methadone Maintenance versus Methadone Detoxification. A 2004 study evaluating the incremental cost-effectiveness of sustained methadone maintenance relative to a 180-day methadone detoxification enriched with intensive psychosocial services followed by drug-free substance use disorder treatment found that methadone maintenance yielded better outcomes, including reduced opioid use and lower subsequent behavioral health care costs, and had a cost-effectiveness ratio of approximately $20,000 per life year gained.^203^

KEY TERMS

Cost-effectiveness study. A comparative analysis of two or more interventions against their health and economic outcomes. These outcomes could be lives saved, illnesses prevented, or years of life gained.

Cost-benefit study. A study that determines the economic worth of an intervention by quantifying its costs in monetary terms and comparing them with the benefits, also expressed in monetary terms. Total benefits divided by total costs is called a cost-benefit ratio. If the ratio is greater than 1, the benefits outweigh the costs.

Methadone Maintenance versus Maintenance with Other Medications. As the use of MAT options has grown, cost-effectiveness studies have compared alternative MAT interventions and MAT compared to medication-free behavioral therapies. For example, a 2015 study examining injectable, extended-release naltrexone compared with methadone maintenance treatment and buprenorphine maintenance treatment for opioid dependence found that extended release naltrexone was more effective among patients remaining in treatment but also more costly than the other options,^227^ totaling an additional $72 per opioid-free day. However, extended-release naltrexone is not off-patent, and therefore these cost findings will likely change when it becomes generic.

Extended Buprenorphine-Naloxone Treatment versus Brief Detoxification. A 2010 study of extended buprenorphine-naloxone treatment for opioid-dependent youth estimated that the cost-effectiveness ratio for buprenorphine compared to detoxification was $29,415 (outpatient treatment program costs for up to 12 weeks) per Quality-Adjusted Life Year (QALY).^228^ Results like this indicate that buprenorphine is highly cost-effective by the standard benchmarks often employed to evaluate clinical and population health interventions ($50,000 to $100,000 per QALY).

KEY TERMS

Quality-Adjusted Life Year (QALY). A measure of the burden of disease used in economic evaluations of the value of health care interventions that accounts for both the years of life lived and the quality of life experienced during those years, relative to quality associated with perfect health.

Buprenorphine-Naloxone versus No Treatment. A 2012 study examined individuals with opioid use disorders who had completed 6 months of buprenorphine-naloxone treatment within a primary care setting. It estimated that office-based buprenorphine-naloxone treatment for clinically stable patients has a cost-effectiveness ratio of $38,107 per QALY compared to no treatment after 24 months.^229^ The cost-effectiveness ratio was measured by calculating the difference in treatment costs between those receiving buprenorphine-naloxone treatment and those that did not and dividing them by the difference in patients' health outcomes.

SBI. A 2014 review of cost-effectiveness studies for alcohol SBI in a primary care setting found considerable variability in the estimated cost-effectiveness ratios and cost savings across studies.^230^ However, almost all the studies found SBI to be cost-effective or to produce cost savings. For example, a 2008 analysis of alcohol SBI in primary care settings found an incremental cost-effectiveness ratio for SBI of $2,413 per QALY gained compared to a do-nothing scenario (in 2014 dollars).^45^ The authors compared the cost-effectiveness of alcohol SBI to 24 other preventive services that have been deemed effective by the USPSTF. Using that comparison, alcohol misuse screening achieved a combined score similar to screening for colorectal cancer, hypertension, or vision (for adults older than age 64), and to influenza or pneumococcal immunization. Because current levels of SBI delivery are much lower than desired, this service deserves special attention by health care professionals and care delivery systems.^45^ Importantly, all of the interventions that have proved to be cost-effective are appropriate for implementation in primary care.

##### Cost-Benefit Analyses

Interventions that prevent substance use disorders can yield an even greater economic return than the services that treat them. For example, a recent study of prevention programs estimated that every dollar spent on effective, school-based prevention programs can save an estimated $18 in costs related to problems later in life.^231^

The Washington State Institute for Public Policy has used a standardized model to estimate the cost-benefit of diverse prevention, early intervention, and treatment programs. Benefit-per-dollar invested ratios for evidence-based interventions (EBIs) include $27.48 for every dollar invested in brief intervention in primary care; $36.71 for brief intervention in a medical hospital; $9.07 for brief intervention in an emergency department; $136.41 for cognitive behavior coping skills therapy; $33.71 for contingency management for substance use; $41.10 for motivational interviewing to enhance treatment engagement; $14.79 for brief marijuana dependence counseling; and $34.90 for brief cognitive behavioral intervention for amphetamine users.^232^ Although some of the 30 interventions studied had smaller benefit-to-cost ratios than others (e.g., $2.18 for methadone maintenance treatment and $1.30 for buprenorphine/buprenorphine-naloxone treatment), all had benefits greater than their costs.

FOR MORE ON THIS TOPIC

See Chapter 3 - Prevention Programs and Policies.

How Much Does Alcohol or Drug Screening and Treatment Cost?

In a 2005 literature review of the economics of substance use disorder treatment, one study highlighted the variability in cost estimates for substance use disorder treatment delivered in specialty settings. For example, they reported per-patient weekly costs ranging from $90 to $208 for standard outpatient treatment; $682 to $936 for residential treatment; and $100 to $125 for methadone maintenance treatment.^162^ Another study, estimated service costs in 170 methadone maintenance treatment programs and found that methadone dosing was $33 per patient per week, individual counseling was $49 per patient per session (approximately 43 minutes per session), and group counseling was $12 per patient per session (approximately 77 minutes per session).^191^ A 2009 study estimated service costs for 70 standard outpatient programs and found that individual counseling was $75 per patient per hour and group counseling was $9 per patient per hour.^192^

A 2012 review of 17 studies on the cost of alcohol screening and brief intervention (SBI), found considerable variability, with costs ranging from $0.56 to $663.74 per screen and $3.76 to $268.16 per brief intervention.^193^ Median costs were approximately $4 per screen and $53 per brief intervention. Costs were typically lower when activity-based costing (assigning the cost and amount of each activity that is part of the intervention) was employed and when the SBI occurred in a primary care setting or was performed by a provider who was not a physician. Additionally, variation was attributed to the wage of the person conducting the screening and the amount of time the screening took. A 2015 study examined costs of SBI for illicit drug use in primary care settings; they estimated that per-person costs were $16.43 for screening, $40.98 for a brief negotiated interview, and $265.49 for an adaptation of motivational interviewing.^194^

In recent years, use of MAT has increased. Recent studies have examined extended-release naltrexone, buprenorphine, and methadone for opioid use disorder treatment.^195-197^ These studies found that health care costs were generally as low or lower for individuals receiving extended-release naltrexone compared to individuals receiving other treatments for opioid use disorder. Individuals with opioid use disorders who received extended-release naltrexone had $8,170 lower costs compared to those receiving methadone maintenance. Individuals receiving buprenorphine with counseling had significantly lower total health care costs than individuals receiving little or no treatment for their opioid use disorder ($13,578 compared to $31,055). However, those receiving buprenorphine plus counseling did not differ significantly in total health care costs when compared to those receiving only counseling (mean health care costs for those receiving counseling only were $17,017).^196^ It is important to note, however, that while some treatments may be less costly, they may also be less effective.

Another study, the Combined Pharmacotherapies and Behavioral Interventions (COMBINE) trial, examined nine treatment alternatives for alcohol treatment, including MAT. They reported mean per-patient cost estimates of $631 for a combined behavioral intervention (CBI) without MAT, $766 for naltrexone with medical management, and $865 for acamprosate with medical management. Combining CBI with a MAT option increased cost estimates to $1,183 for naltrexone plus CBI and $1,285 for acamprosate plus CBI.^198^ However, in the COMBINE study, naltrexone combined with medical management was found to be the most cost-effective treatment. While other treatments may be less costly, they are also somewhat less effective.

* All costs in this sidebar are calculated in 2014 dollars.

## Financing Systems for Substance Use Disorder Services

In 2013, about three-quarters of all general health care purchased in the United States was paid for by private insurance, Medicare, or Medicaid. The rest was covered by consumers paying out-of-pocket, by other federal health grants, and by programs and other insurance provided by the DoD, Department of Veterans Affairs, and other state and local programs.^211^ In the case of treatment for substance use disorders, only about 45 percent of spending was through private insurance, Medicare, or Medicaid. In 2014, the largest share of substance use disorder treatment financing was from state (non-Medicaid) and local governments (29 percent).^211^

### Private Insurance

In 2014, 66.0 percent of individuals in the United States had private health insurance, either obtained through employers or individually.^212^ Approximately 9 percent of insured individuals met criteria for a diagnosis of substance use disorder, as defined by the Fourth Edition of the Diagnostic and Statistical Manual of Mental Disorders (DSM-IV).^214^ However, in 2013, only 7 percent of privately insured individuals aged 12 and older with a substance use disorder received treatment from specialty treatment providers,^214^ and total spending on treatment for substance use disorders makes up only 0.6 percent of overall private insurance spending.

Coverage of substance use disorder services under private insurance has waxed and waned over the past 30 years. During the 1980s, insurance benefits and specialty addiction providers expanded,^215,216^ and from 1986 to 1992, substance use disorder spending grew by 6.7 percent annually, a substantial increase but still significantly below the 10.3 percent annual growth rate of all health care spending over the same period. This expansion was followed by managed care restrictions on reimbursement for substance use disorder treatment in inpatient settings, such as limitations on length of residential rehabilitation stays (a common treatment regimen).^217,218^ As a result, inpatient substance use disorder treatment services declined from accounting for 50 percent of total spending for substance use disorder treatment in 1986 to only 19 percent in 2014 (Figure 6.4). Further, the share of substance use disorder financing from private insurance dropped dramatically between 1986 and 2014, from 32 percent in 1986 to 13 percent in 2005; this was followed by an increase to 18 percent in 2014, likely due to MHPAEA and qualified health plan coverage now being available through the Affordable Care Act.^211^

Figure 6.4 Percentage Distribution of Spending on Substance Misuse Treatment by Setting, 1986-2014

Source: Substance Abuse and Mental Health Services Administration, (2016).^167^

Line graph shows the percentage distribution of spending on substance misuse treatment by setting. During the 1980s, insurance benefits and specialty addiction providers expanded, and from 1986 to 1992, substance use disorder spending grew. This expansion was followed by managed care restrictions on reimbursement for substance use disorder treatment in inpatient settings. As a result, inpatient substance use disorder treatment services declined from accounting for 50 percent of total spending for substance use disorder treatment in 1986 to only 19 percent in 2014. In that same time period spending on outpatient treatment increased from 27% of all substance use disorder sending to 40%, residential treatment spending increased from 17% to 27%, insurance administration spending increased from 5% to 8%, and prescription drug spending increased from less than 1% to 5%.

### Medicaid

Approximately 20 percent of people in the United States have health coverage through Medicaid, a joint federal and state health coverage program that provides medical assistance for children, families, and individuals with low income and limited resources; an estimated 12 percent of adult Medicaid beneficiaries have a substance use disorder.^212^ The federal government finances approximately 60 percent (national average) of Medicaid and the states finance the balance.^220^ The federal medical assistance percentages (or “match”) vary significantly among states, based on the state's per capita income and other factors.

FOR MORE ON THIS TOPIC

See the section on “A Growing Impetus for Integration” earlier in this chapter.

The federal government establishes basic requirements that states must follow in designing their Medicaid programs, including some mandated services that must be covered and guidance regarding payment rate-setting and contractual arrangements, eligibility and quality standards, and provision of optional services.^221^ However, state implementation decisions can have a significant impact on what services are covered and for whom. States can choose to cover or not cover specific treatments or to place restrictions on covered services. In the past, some states have not included certain critical substance use disorder treatment options in their benefit packages (e.g., methadone), or they have restricted the doses or length of treatment, or added requirements such as prior authorization processes to obtain some treatments (e.g., buprenorphine). In many states, Medicaid also does not cover residential treatment, especially for adults.

For those who are eligible and have substance use disorders, Medicaid is an extremely important program, as it can cover many services that such individuals may need, such as crisis services and many preventive services. In addition, while Medicaid does not provide payments for housing (e.g., rental subsidies) or other room and board costs in the community, states can supplement Medicaid coverage with supportive services to help people maintain housing in collaboration with housing authorities.^222^

In states that did not expand Medicaid, racial and ethnic minorities are disproportionately affected. In addition, in these states, young adult single males—a group with high rates of substance use disorders-are ineligible for Medicaid benefits.^223^

An estimated 14 to 15 percent of uninsured individuals nationwide who could be newly eligible for Medicaid coverage under the Affordable Care Act have a substance use disorder.^35^ If they obtain substance use disorder treatment, this will lead to an additional 450,000 previously uninsured individuals having access to affordable substance use disorder treatment.

### Medicare

Medicare covers almost all individuals aged 65 or over as well as those eligible because of disabilities. Approximately 56.2 million, or 17 percent of individuals in the United States, have Medicare.^224^ Approximately 3 percent of Medicare beneficiaries and 6 percent of those who are eligible for both Medicare and Medicaid have a substance use disorder in any given year.^226^ Of these, 19.3 percent received specialty substance use disorder treatment, including individual, group, and/or family therapy.^225^ In general, Medicare Parts A and B (or private Medicare Advantage plans under Part C) cover inpatient (but not residential) and outpatient services for substance use disorders, as well as substance use disorder screening and brief intervention. Prescription drug treatment is generally covered for beneficiaries enrolled in Medicare Part D (or a Medicare Advantage plan that includes drug coverage). Medicare does not cover outpatient use of oral methadone for substance use disorders, but Part D can include coverage for medications, such as disulfiram, naltrexone, acamprosate, and buprenorphine.

### Other Federal, State, and Local Funding

Although insurance coverage is critical to improving access to and integration of services for individuals with substance use disorders, it is unlikely to cover all the services that such individuals may need, such as crisis services (e.g., emergency treatment intervention), housing, supported employment, and many community prevention programs and services (e.g., school-based prevention programs). These services are often supported by federal, state, and local governments and non-profit organizations, financed through general revenues and the SAMHSA Substance Abuse Prevention and Treatment Block Grant (SABG).

### Uninsured Individuals

Research has shown that uninsured individuals have higher unmet medical needs than do insured individuals, and those without insurance also have higher rates of substance use disorders than do individuals with insurance.^226^ Among uninsured individuals, 12 percent met DSM-IV criteria for a substance use disorder.^214^

Financing Community Prevention

##### Federal Funding Streams

Funds from federal block grants to states for substance use disorder treatment services (such as the SABG, which is often used for prevention activities) and for maternal, child, and adolescent health services (Title V of the Maternal and Child Health Services Block Grant) may be used to fill the gaps in treatment services not covered by insurance. These funds also finance treatment for people without insurance and support community prevention activities.^233^

In addition, federal funding for certain community prevention programs encourages public-private partnerships and community collaboration to improve health outcomes. Grants are used to increase screening, counseling, workplace wellness programs, and community prevention. In addition, federal funding for community prevention programs is available through the Drug Free Communities Support Program, which is funded by the White House Office of National Drug Control Policy and administered by SAMHSA.^234^

FOR MORE ON THIS TOPIC

See Chapter 3 - Prevention Programs and Policies.

Although investments in prevention have repeatedly demonstrated favorable economic returns,^235^ primary prevention for all health conditions still accounts for less than 5 percent of overall health spending in the United States. Prevention should be seen as an appropriate health cost to be covered by insurance. Current funding options for community prevention, described below, include grants from hospital and health system foundations, hospital-based community benefit programs, tax earmarks, and targeted state programs.

##### Hospital and Health System Foundation Grants

Foundations formed from the conversion of tax-exempt non-profit hospitals and health systems into for-profit entities are required by federal law to invest in health-related activities within the community area served by that hospital.^236^ These “health conversion foundations” or “new health foundations” now exist in more than 200 communities in the United States, and they are a potential source of funding for programs relating to the prevention and treatment of substance misuse.^237^

##### Non-profit Hospital Community Benefits

Beginning in 1994, tax-exempt hospitals have been required to provide benefits to the community in return for not paying taxes.^238^ The Affordable Care Act clarified community benefit expectations for all non-profit hospitals. Tax-exempt hospitals must: (1) conduct a community health needs assessment at least once every 3 years; (2) involve public health experts and representatives of the community served by the facility in the needs assessment; (3) make the results of the assessment available to the public; (4) develop an implementation strategy to address each of the community health needs identified through the assessment; and (5) report yearly to the Internal Revenue Service.^239^ The Secretary of the Treasury, in collaboration with the Secretary of Health and Human Services, must report annually to Congress on, among other things, hospitals' levels of charity care, related costs, and community benefit activities.

Although hospitals have flexibility in their definition of “community served by the facility,” they are expected to define community by the geographic location, not by the demographic or geographic profiles, of patient discharges. Many states also have community benefit programs that must be synchronized with the requirements of the Affordable Care Act.^240^ The 1997 IOM report Improving Health in the Community outlined how multiple stakeholders can conduct a community health assessment and share accountability for health outcomes of specific populations.^241^

##### Local or State Substance Use Tax Earmarks

In certain jurisdictions, direct funds from a local or state tax can be earmarked for substance misuse prevention in the same way as tobacco taxes are currently used for public health and health programming in many states.^242^ Jackson County, Missouri, is an example of a local jurisdiction with a dedicated funding stream for substance use problem prevention.^243^

Jackson County, Missouri, first introduced a dedicated sales tax in 1989 to tackle drug use and drug-related crime. This later became known as COMBAT—Community-Backed Anti-Drug Tax—and enabled Jackson County to approach the impact of drugs on individuals and communities as both a legal issue and a public health crisis. It was renewed for seven years in 2009, and the one-quarter of one-cent sales tax generates over $20 million per year. The funds are used for a variety of prevention, treatment, and anti-drug and drug-related crime prevention programs. In addition, Florida and Indiana, among other states, earmark alcohol taxes for child and adolescent substance use-related services.^244^

##### State Prevention Trust Funds

The Massachusetts Legislature passed the first state-based prevention fund, called the Prevention and Wellness Trust Fund, in 2012 as part of a health cost control bill. Funded through a one-time $57 million assessment, the Trust Fund is used to reduce the prevalence of preventable health conditions and lower health care costs. Grantees have a strong focus on extending care beyond clinical sites into the community.^245^

## Challenges Facing the Integration of Substance Use Services and Health Care

It is clear that integrating substance use disorder services with mainstream health care is beneficial for individuals and communities and that health reform is encouraging this trend. However, several key challenges must be addressed if integration is to be fully successful. Specifically:

- The substance use disorder treatment system is underprepared to support care coordination;
- The primary care system has been slow to implement MAT as well as prevention, early identification, and other evidence-based recommendations;
- The existing health care workforce is already understaffed and often lacks the necessary training and education to address substance use disorders; and
- The need to protect patient confidentiality creates hurdles for sharing of information.

### The Infrastructure of the Substance Use Disorder Treatment System Is Underdeveloped

The Congressional Budget Office currently estimates that by 2026, 24 million Americans who would otherwise be uninsured will obtain health insurance coverage as a result of the Affordable Care Act.^246^ For those insured by insurance plans sold to small employers and in the individual market, substance use disorder services are considered an essential health benefit. As a result, the Affordable Care Act, coupled with MHPAEA is projected to expand access to mental and behavioral health services to more than 60 million Americans.^247^

However, the specialty care substance use disorder treatment system faces challenges along with these new opportunities.^248^ That system is changing as health systems respond to new requirements, begin to provide services internally, and develop new contracting mechanisms.^249^ Public substance use disorder systems are also changing as they are presented with new funding options under Medicaid and other funding sources.^248^

Nationally representative data from the 2014 National Drug Abuse Treatment System Survey underscore the importance (but also the difficulty) of integrated care efforts.^250^ Directors at only 15 percent of responding units reported signed contracts to work with a medical home, meaning that less than 50 percent of patients were receiving treatment in a program that was prepared to integrate general health care.^250^ These data showed particularly dramatic differences between Medicaid expansion and non-expansion states,^250^ with Medicaid expansion acting as a key driver of integrated care. Fifty-five percent of addiction treatment patients in expansion states are receiving care in organizations that at least have contractual linkages to some medical or health home arrangement.^251^

Substance use disorder treatment organizations currently face significant challenges in engaging in care coordination with other types of providers. Because these organizations have traditionally been organized and financed separately from general health care systems, the two systems have not routinely exchanged clinical information. Efforts to increase HIE are constrained by the relatively low use of EHRs. In a 2012 survey of treatment programs to assess their readiness for health reform, 63 percent described their organizations' adoption of EHRs as having not yet begun, or only in the early stages.^252^ A 2015 study reported that substance use disorder treatment organizations across the nation are poorly positioned to work effectively with health homes or other health professionals.^253^ Not surprisingly, organizations with annual budgets less than $5 million were less likely than larger ones to report high readiness.^254^ Some evidence also suggests that publicly funded substance use disorder treatment centers are less technically proficient and less responsive to making changes than for-profit treatment facilities. For example, private, for-profit treatment facilities were significantly more likely to be early adopters of buprenorphine therapies than were their public or private non-profit peers.^255^ Substantial technical assistance and investments in staff and information technology are needed, yet substance use disorder treatment providers receive relatively little assistance or resources from federal or state agencies to make these changes.^253^ However, a February 29, 2016 State Medicaid Director Letter outlined that states, subject to prior approval by the Centers for Medicare & Medicaid Services (CMS), may use federal matching funds to connect Meaningful Use Eligible Medicaid Providers to other providers including substance use disorder treatment providers to support HIE and care coordination. This offers promise for increasing adoption and use of health IT by behavioral health providers.^256^

Another challenge for effectively coordinating care relates to the need for specialty substance use disorder treatment programs to comply with substance abuse confidentiality regulations (42 CFR Part 2) and state privacy laws when implementing health IT systems. In addition, substance use disorder treatment organizations face the challenge of communicating with non-health care personnel including those in social service, criminal justice, and educational facilities and even when EHRs are in place these systems lack interoperability (the ability to effectively exchange digital health information from an EHR in a common format) with the information systems used by social service organizations, hindering communication.

Medical homes are most likely to pursue contractual arrangements with large and technologically sophisticated organizations that are best equipped to meet their needs for timely clinical and administrative information. The move toward integrated care is therefore likely to accelerate consolidation of substance use disorder treatment programs, which may hasten the adoption of new technologies and processes among sophisticated providers. Particularly in combination with expanded insurance coverage, this trend may attract new partnerships, for example between ACOs, which are integrated delivery systems, and more sophisticated specialty addiction providers. Yet, the same patterns may harm smaller providers, some of whom offer the only culturally competent services for particular patient groups, such as services tailored for specific racial and ethnic populations, sexual and gender minorities, or women in need of trauma-related residential services.^257-259^

### Slow Implementation of Pharmacotherapies for Use in Treatment

One key challenge for integrating substance use treatment and health care is that implementation of pharmacotherapies (i.e., MAT) in primary care has been slow.^260^ In part, this is due to the fact that health insurers individually determine whether they cover substance use medications^261^ and treatment providers may not offer medications to patients with substance use disorders. A study of 2009–2010 national treatment center data found that only 25 percent of substance use disorder treatment centers offered medications for alcohol and/or drugs: 24.5 percent offered buprenorphine, 18.7 percent offered acamprosate, 17.3 percent offered tablet naltrexone, 15.9 percent offered disulfiram, 9.1 percent offered injectable naltrexone, and 9.0 percent offered methadone.^262^ Studies have found that only 25 percent of private, for-profit treatment centers used buprenorphine, 15.6 percent used acamprosate, and 15.7 percent used disulfram. Research suggests that whether treatment programs offer MAT is influenced by a number of organizational and state-level factors, including differences in organizational size, whether the treatment program is in a hospital setting, whether psychiatric medications are prescribed, whether the program has access to prescribing staff, and whether state Medicaid policies support the use of generic drugs.^263-266^

Another medication, extended-release injectable naltrexone, approved by the FDA for use in treating individuals with opioid use disorders, is underutilized by programs. For example, one study found that only three percent of United States treatment programs used it for opioid use disorders.^267^ In contrast, buprenorphine for opioid use disorder is becoming more established, although it too is underused. One study found that between 2005 and 2011, its use for detoxification in specialty opioid treatment programs (OTPs) increased from 36 percent of programs in the sample to 46 percent; its use for maintenance increased from 37 percent of programs in the sample to 53 percent.^268^ One deterrent to rapid expansion of access to buprenorphine has been the limit on the number of patients a certified physician can treat with buprenorphine. A recent study found that raising this limit further, rather than increasing the number of specialty addiction programs or waivered physicians, may be the most effective way to increase buprenorphine use.^269^ Up until July 2016, qualified practitioners were allowed to treat a maximum of 30 patients at a time the first year and up to 100 patients at a time thereafter. On July 6, 2016, HHS issued a final rule for “Medication Assisted Treatment for Opioid Use Disorders,” which increased access to buprenorphine medications in the office-based setting as authorized under the Controlled Substances Act 21 U.S.C. 823(g)(2).^270^ The rule allows eligible practitioners to request approval to treat up to 275 patients under section 303(g)(2) of the Controlled Substances Act.

### Limited Implementation of Prevention, Early Identification, and Other Evidence-based Recommendations

Another key challenge is that primary care settings have not yet routinely implemented recommended preventive health and intervention services related to substance misuse. Currently, the Affordable Care Act requires that all non-grandfathered health plans must cover, without cost-sharing, certain preventive health services recommended by the USPSTF,^271^ and women's preventive services and preventive services for infants, children, and adolescents in guidelines supported by HRSA As discussed earlier, the USPSTF recommends alcohol screening and counseling for adults. However, none of the 22 women's health guidelines, which are being updated at the time of this Report, or 26 children/adolescent guidelines supported by HRSA include a screening requirement related to alcohol use.^42,43^

Studies of SBIRT for alcohol use problems have identified many implementation challenges.^272-277^ Some of the most commonly noted challenges include the intense time constraints experienced in modern clinical settings,^276^ the multiple competing preventive and clinical priorities faced by providers,^278^ inadequate health care professional training on alcohol SBI techniques,^277^ and providers' feelings that they are unable to address sensitive health issues adequately.^279^ Currently, only about one in six adults in the United States reports being asked about their drinking,^280^ and less than 10 percent of health plans verify that screening is performed.^281^ In pediatric health care settings, other issues, especially restrictions on disclosure of confidential information to parents (which varies by state), also pose challenges.^282^

The USPSTF currently considers the evidence to be insufficient to support screening or behavioral interventions for substance misuse problems in pediatrics.^43,283^ However, a number of studies, funded by the National Institutes of Health (NIH) and foundations such as The Conrad N. Hilton Foundation, are currently underway that could add to the evidence base. Major pediatric medical organizations, including the American Academy of Pediatrics, strongly recommend addressing these issues regularly at each well-adolescent visit and appropriate urgent care visits.^284^ Bright Futures, a HRSA-funded program, sets Recommendations for Preventive Pediatric Health Care and includes alcohol and drug use screening within its recommended schedule for an annual clinical preventive visit for adolescents and young adults between the ages of 11 and 21. The Affordable Care Act requires health plans to cover, at no out-of-pocket cost to families, the preventive care services outlined in this schedule. Bright Futures discusses how to incorporate screening into the preventive services visit for these age groups. In addition, SAMHSA recommends universal screening and brief intervention and referral to treatment at each well-visit,^285^ and the National Institute on Alcohol Abuse and Alcoholism (NIAAA) recommends universal screening for alcohol misuse.

Screening and brief intervention for substance misuse is also consistent with the prevention activities recommended in the 2009 IOM report Preventing Mental, Emotional, and Behavioral Disorders Among Youth: Progress and Possibilities.^286^ Yet screening is seldom addressed according to guidelines or with appropriate evidence-based practices,^287,288^ and even when screenings are conducted, appropriate follow-up is often not provided.^289,290^ However, SBIRT can be effectively implemented, both for adults and adolescents,^291,292^ and it is likely that many more systems will do so to comply with new requirements by The Joint Commission and in the Affordable Care Act. The Joint Commission Requirements mandate that hospitals offer inpatients brief counseling for alcohol misuse and follow-up, and measure the provision of counseling as one of the core measures for hospital accreditation. Primary care teams that include non-physician providers (e.g., nurses, health educators) are increasingly used for substance use disorder, mental health, and other disease management, and they have proved to be a viable approach for implementing alcohol SBIRT.^291,293-298^

Meeting Challenges in Primary Care

Several large health systems, such as the Veterans Health Administration and Kaiser Permanente, have successfully implemented primary care-based alcohol SBI in a sustainable manner.^299-302^ They have used a variety of approaches to accomplish this goal, including:

- Integrating screening, assessment, and clinical decision support tools in the EHR;
- Establishing interdisciplinary (primary care, substance use disorder treatment, and mental health) teams to guide integration and collaboration;
- Ensuring health system leadership support; and
- Using training curricula, targeted communications materials, robust performance feedback reporting for physicians and other staff, and existing financial incentives.^278,291,303-305^

These approaches can also be implemented in emergency departments and in obstetrics and gynecology departments.

### The Health Care Workforce Is Limited in Key Ways

#### Workforce Shortages

Data on the substance use workforce are incomplete.^306^ Although HRSA collects data on mental health workforce shortage areas, the agency does not collect similar data on the substance use disorder treatment workforce. Nevertheless, it is clear that the workforce is inadequate, as evidenced by its uneven geographic distribution (with rural areas underserved), access barriers for adolescents and children, and recruitment challenges across the treatment field. Moreover, the workforce is aging. For example, 46 percent of psychiatrists are older than age 65.^307,308^ As of June 2016, more than three-quarters of United States counties had severe shortages of psychiatrists and other types of health care professionals needed to treat mental health and substance use disorders.^309^ The scarcity of providers who can provide culturally competent services for minority populations and the high turnover rate, both noted in SAMHSA's 2013 Report to Congress^307^ and other studies, exacerbate the workforce shortage.^310,311^

Recent reforms may strain the current workforce in an already overstretched health care system working to address treatment and prevention strategies. A recent study documented staffing models in primary care practices and determined that, even among those designated as patient-centered medical homes, fewer than 23 percent employed health educators, pharmacists, social workers, nutritionists, or community service coordinators, and fewer than half employed care coordinators.^312^ The opioid epidemic has made the shortage of these types of health care professionals an even larger problem.^310^ Thus, it is crucial that health care professionals are given comprehensive training on the prevention and treatment of substance use disorders when patients present with comorbid conditions.^32^

The IOM's 2006 report Improving the Quality of Health Care for Mental and Substance Use Conditions,^32^ which adapted Crossing the Quality Chasm to address mental and substance use conditions, noted that a critical concern in attracting a skilled workforce is the low salary structure of the substance use disorder treatment workforce. Much of the public treatment system is funded by Medicaid and SAMHSA's SABG. In practice, the Block Grant is used broadly, and Medicaid less and only with a subset of providers. It is not yet clear whether the integration of substance use disorder treatments in general health care will help to address salary structure.

#### Composition and Education

An integrated health and substance use disorder treatment system requires a diverse workforce that includes substance use disorder specialists, physicians, nurses, mental health treatment providers, care managers, and recovery specialists. This workforce also includes peer recovery coaches (a reimbursable service under some state Medicaid programs), health educators, social workers, and other staff who are trained to deliver timely mental health and substance use-related health interventions, such as SBI.^32^ However, Medicare, and in some states Medicaid, restricts “billable” health care professionals to physicians (including psychiatrists), nurse practitioners and clinical nurse specialists, physician's assistants, clinical psychologists, clinical social workers, and certain other specified practitioners, and does not include as billable the multiple other licensed and certified professionals who are trained to provide services for substance use disorders.

As substance use disorder treatment and general health care become more integrated, clinical staff in both systems will need to expand their scope of work, operate in an integrated manner with a variety of populations, and shift their treatment focus as needed.^313-315^ Being able to assess substance use disorder severity and co-occurring mental health and physical health problems will be important in each setting. Health care professionals moving from the specialty workforce into integrated settings will require specific training on treatment planning and care coordination and an ability and willingness to work under the leadership of medical staff. This transition to a highly collaborative team approach, offering individually tailored treatment plans, presents challenges to the traditional substance use disorder treatment workforce that is used to administering standard “programs” of services to all patients. Working in teams with the broad mandate of improved health is not currently commonplace and will require collaboration among professional and certification bodies. Incorporating peer workers, who bring specific knowledge of patients' experiences and needs and can encourage informed patient decision making, into teams will also require further adjustment.

Improving the Quality of Health Care for Mental and Substance Use Conditions also discussed the shortage of skills both in specialty substance use disorder programs and in the general health care system.^32^ Of special concern was the inadequacy of substance use education as part of medical school training: Only 8 percent of medical schools had a separate required course on addiction medicine and 36 percent had an elective course;^32,316^ on average, the residency curriculum for psychiatrists included only 8 hours on substance use disorders.^32,317^ Schools of social work and psychology also provided little, and sometimes no, mandatory education on substance use-related problems.^32^ The situation does not appear to have substantially changed since that report was released, although the recent recognition of addiction medicine as a subspecialty by the American Board of Medical Specialties should provide increased focus and perhaps attract more physicians to this field.

#### Workforce Development and Improvement

The Annapolis Coalition on the Behavioral Health Workforce provided a framework for workforce development in response to the challenges described above,^318^ focusing on broadening the definition of “workforce” to address needed changes to the health care system. Currently, 66 organizations license and credential addiction counselors,^319,320^ and although a consensus on national core competencies for these counselors exists,^321^ they have not been universally adopted. Credentialing for prevention specialists exists through the International Certification & Reciprocity Consortium,^322,323^ but core competencies for prevention professionals have not been developed. Without a comprehensive, coordinated, and focused effort, workforce expansion and training will continue to fall short of the challenge of meeting the needs of individuals across the continuum of service settings.

HRSA has taken a number of steps to address these workforce challenges as part of its mission to prepare a diverse workforce and improve the workforce distribution to increase access for underserved communities. Among its many programs, HRSA awards health professional and graduate medical education training grants and operates scholarship and loan repayment programs. Of particular note is the National Health Service Corps, where, as of September 2015, roughly 30 percent of its field strength of 9,683 was composed of behavioral health providers, meeting service obligations by providing care in areas of high need.^324^ HRSA is also putting increased emphasis on expanding the delivery of medication-assisted treatment, increasing SBI, and coordinating RSS. The development of the workforce qualified to deliver these services and services to address co-occurring medical and mental disorders will have significant implications for the national workforce's ability to reach the full potential of integration.

### Protecting Confidentiality When Exchanging Sensitive Information

Effectively integrating substance use disorder treatment and general health care requires the timely exchange of patient health care information. In the early 1970s, the federal government enacted Confidentiality of Alcohol and Drug Abuse Patient Records (42 U.S.C § 290dd-2), and released regulations (42 CFR Part 2) to protect the confidentiality of substance use disorder treatment data. These privacy protections were motivated by the understanding that discrimination attached to a substance use disorder might dissuade people from seeking treatment, and were enacted in the context of patient methadone records being used in criminal cases. Due to its targeted population, 42 CFR Part 2 provides more stringent federal protections than most other health privacy laws, including the Health Insurance Portability and Accountability Act (HIPAA – 45 CFR Part 160 and 164). HIPAA does not require patient authorization to share health information for purposes of treatment, payment, or health care operations. With 42 CFR Part 2, patient consent is required to share and use patient identifying information and any information that could be used to identify someone as having, or having had, a substance use disorder, such as payment data.

Given the long and continuing history of discrimination against people with substance use disorders, safeguards against inappropriate or inadvertent disclosures are important. Disclosures to legal authorities can lead to arrest, loss of child custody, or relinquished parental rights. Disclosures to insurers or to employers can render patients unable to obtain disability or life insurance and can cost patients their jobs. Currently, persons with substance use disorders involving illicit drugs are not protected under anti-discrimination laws, such as the ADA.

However, exchanging treatment records among health care providers has the potential to improve treatment and patient safety. For example, in the case of opioid prescribing, a study in health systems of long-term opioid users found those with a prior substance use disorder diagnosis received higher dosages and were co-prescribed sedative-hypnotic medications—which can increase the risk for overdose—more often. Because of privacy regulations, it is likely that physicians were not aware of their patients' substance use disorders.^52^ In most states, these challenges are now partially addressed through prescription drug monitoring programs (PDMPs), which are also helping to support care coordination.

PDMPs are state-run databases that collect prescribed and dispensed controlled prescription drug information and give prescribers and pharmacists access to a person's controlled substance prescription history. Authorized providers can check the database before prescribing or dispensing. However, PDMPs have many limitations. They do not include information about methadone used for opioid use disorders, which is exclusively dispensed at OTPs, or from programs covered by 42 CFR Part 2. While disclosure of patient-identifying information that is subject to 42 CFR Part 2 is allowable, it would require written patient consent, and re-disclosures of this information would not be permitted unless the patient consents. However, any information in the PDMP database could be potentially seen by anyone who has access to the state PDMP data and therefore may be in violation of Part 2. In addition, PDMPs only collect prescription information as allowed by their state laws, in most cases controlled substances Scheduled II through IV or V, and thus health care professionals may not be aware of other prescriptions their patients are receiving.^326^ Further, the extent to which the PDMP systems are effectively designed and used is not fully known.^327^

As EHR interoperability and the exchange of health information increases, best practices must be developed for handling substance use disorder treatment data, consistent with state and federal privacy laws. It will be important that EHR technologies develop the functionality to share health information electronically while complying with HIPAA, 42 CFR Part 2, and state privacy statutes. One approach to sharing protected data electronically is called Data Segmentation for Privacy (DS4P), an optional criterion under the Office of the National Coordinator for Health Information Technology's (ONC's) 2015 Edition Health IT Certification Criteria.^325^ SAMHSA recently developed an open source tool called Consent2Share (C2S), which is based on DS4P and allows patients to electronically create and manage consent directives specifying which providers can access their data.

## Promising Innovations That Improve Access to Substance Use Disorder Treatment

Clearly, integrating health care and substance use disorder treatment within health care systems, as well as integrating the substance use disorder treatment system with the overall health care system, are complex undertakings. The good news, however, is that a range of promising health care structures, technologies, and innovations are emerging, or are being refined and strengthened, under health reform. These developments are helping to address challenges and facilitate integration. In so doing, they are broadening the focus of interventions beyond just the treatment of severe substance use disorders to encompass the entire spectrum of prevention, treatment, and recovery. These promising developments include:

- Medicaid innovations;
- EHRs and health IT;
- Disease registries; and
- Substance misuse and substance use disorder prevention through a public health approach.

### Medicaid Innovations

Medicaid is not only an increasing source of financing for substance use disorder treatment services, it has become an important incubator for innovative substance use disorder financing and delivery models that can help integrate substance use disorder treatment and mainstream health care systems. Within the substance use disorder treatment benefit, and in addition to providing the federally required set of services, states also may offer a wide range of recovery-oriented services under Medicaid's rehabilitative services option. These services include therapy, counseling, training in communication and independent living skills, recovery support and relapse prevention training, skills training to return to employment, and relationship skills. Nearly all states offer some rehabilitative mental health services, and most states offer the rehabilitation option for substance use disorder services.^328^

CMS provides various authorities by which states can structure their Medicaid programs, thus providing mechanisms for states to expand and improve their substance use disorder treatment delivery system: This includes authorities to:^328-330^

- Offer coordinating, locating, and monitoring activities broadly and create incentive payments for providers who demonstrate improved performance on quality and cost measures (section 1905(t));
- Establish Alternative Benefit Plans (ABPs), which require that substance use disorder services are included and comply with mental health parity standards (section 1937);
- Establish voluntary or mandatory managed care plans, which require parity protections for enrolled individuals (sections 1915(a) and 1915(b) authorities, and section 1932 State Option to Use Managed Care);
- Provide home and community-based services and supports (sections 1915(c), 1915(i), 1915(j), and 1915(k));
- Develop health homes (section 1945 Health Home State Plan Option); and
- Conduct demonstrations to test policy innovations (section 1115).

Recently, CMS gave states new opportunities to design service delivery systems for substance use disorders through demonstration projects under section 1115. This initiative is designed to support states to provide coverage for the full continuum of care; ensure that care is delivered consistent with the ASAM Treatment Criteria; design strategies to coordinate and integrate care; and support quality improvement programs. In 2014, CMS launched the Medicaid Innovation Accelerator Program, which aims to improve “health and health care for Medicaid beneficiaries by supporting states' efforts to accelerate new payment and service delivery reforms.”^331^ CMS identified substance use disorders as the program's first area of focus. The agency is providing technical and program support to states to introduce policy, program, and payment reforms to identify individuals with substance use disorders, expand coverage for effective treatment, expand access to services, and develop data collection, measurement, and payment mechanisms that promote better outcomes. Medicaid is also encouraging the trend to integration in other ways, including supporting new models for delivering primary care, expanding the role of existing community-based care delivery systems, enacting mental health and substance use disorder parity for Medicaid and Children's Health Insurance Program (CHIP) as included in the final rule that CMS finalized in March 2016. This rule requires that Medicaid enrollees in managed care organizations (MCOs) and in ABPs have access to coverage for mental health and substance use services that is in parity to coverage of medical benefits and will benefit the over 23 million people enrolled in MCOs, Medicaid ABPs, and CHIP.

#### Health Homes

Health homes are grounded in the principles of the primary care medical home, which focuses on primary care-based coordination of diverse health care services, and patient and provider engagement. The Affordable Care Act created an optional Medicaid State Plan benefit allowing states to establish health homes to coordinate care for participants who have chronic health conditions. Health homes operate under a “whole-person” philosophy that involves integrating and coordinating all primary, acute, behavioral health, and long-term care services to address all the individual's health needs.

Beneficiaries with chronic conditions are eligible to enroll in health homes if they experience (or are at risk for) a second chronic condition, including substance use disorders, or are experiencing serious and persistent mental health conditions.^332^ Such care arrangements are particularly pertinent to individuals with substance use disorders who experience severe co-occurring physical and/or mental disorders. These arrangements emphasize integration of care, targeting of health home services to high-risk populations with substance use and mental health concerns, and integration of social and community supports with general health services.

As of January 2016, 19 states and the District of Columbia had established Medicaid health home programs – covering nearly one million individuals – and nearly a dozen additional states had plans for establishing them. States such as Vermont, Maryland, and Rhode Island have implemented health home State Plan Amendments (SPAs) with substance use-related provisions.^333^ Seven other states specifically identify individuals with substance use disorders as a target population.^334^ Many other SPAs include behavioral health care arrangements that encompass substance use disorders.^334,335^

States that implement Medicaid health homes receive substantial federal subsidies, including 90 percent federal matching rates for health home services during the first eight quarters after the effective date of health home coverage under the Medicaid state plan, covering comprehensive case management, coordinating services and health promotion, comprehensive transitional care from inpatient to other settings, individual and family support services, linkage and referrals to community-based services, and health IT.^336,337^

In some settings, these integrated care models are associated with reduced cost and improved cost-effectiveness,^338^ and research is underway to test new models. Recognizing the important role that these kinds of integrated care arrangements can play, the American Academy of Family Physicians and SAMHSA have issued reports promoting the inclusion of substance use and mental health services in patient-centered medical homes and related efforts.^248,339,340^ Much remains to be implemented in both public and private systems, but health systems are responding in a variety of ways to address substance use issues and their efforts will be key in improving treatment quality and outcomes.^249,341^

#### Accountable Care Organizations

Another Affordable Care Act provision created opportunities to encourage the integration of primary and specialty care, as well as community and public health systems, by establishing integrated delivery systems known as ACOs.^238^ ACOs include health care professionals and hospitals that are responsible, together, for the total health of their patient populations. The motivation behind ACOs is that by being responsible for the overall health of patients and coordinating the care they provide, the collaborating health systems can achieve the “three part aim” of better quality care for individuals, reduced per capita costs, and improved population health.^342^ Because ACOs can include a range of different types of providers across a defined region, they interpret “population health” in two broad ways: as a “panel population,” referring to all the patients participating in the health delivery system, and as a “geographic population,” referring to all who live in the ACO's defined geographic catchment area.^343^

An ACO that focuses on the larger community is called an accountable care community (ACC). ACCs are an important variation on the ACO model because, by focusing on the larger community, they can address the social determinants of health and health disparities that have such a profound impact on community members' health and well-being, including their risks for substance misuse, substance use disorders, and related health consequences.^344^

Initially developed as a model under Medicare, ACOs have now also been encouraged under Medicaid for its covered populations.^345-348^ The CMS State Innovation Models (SIM) Initiative supports the development and testing of state-based models for multi-payor payment and health care delivery system transformation for improving the performance of health systems. An underlying assumption of the new service delivery and payment models funded in the SIM states is that they will be more effective and produce better outcomes when implemented as part of a broad-based, statewide initiative that brings together multiple payors and stakeholders, and when they use the levers of state government to effect change.

The SIM states are leading the implementation of accountable care systems for Medicaid populations that embrace population health (for SIM states, this is defined as health of the community in a geographic area as opposed to the population of patients in the health delivery system). Several states have adopted ACC models that support integration of medical health care services with public health and community-based programs.^238^ For example, Akron in Summit County, Ohio, set up one of the first ACCs to implement community-wide public-private partnerships to improve the health of the overall population.^349^ Maine's accountable communities, Oregon's CCOs, and Minnesota's accountable communities are partnering with local public health authorities and other community entities to achieve this goal.^350^

Oregon's CCOs are a network of all types of health care professionals (physical health care, addiction and mental health care, and dental care providers) who have agreed to work together to serve people who receive health care coverage under Oregon's Medicaid plan, which is called Oregon Health Plan. The Oregon Health Authority publishes regular reports on quality, access, and progress toward benchmarks in both prevention and treatment.^351^ Oregon Medicaid CCOs are currently reporting, and showing progress on, three quality measures specific to substance use: use of SBIRT, initiation of substance use treatment, and engagement in treatment.

#### Federally Qualified Health Centers

Increased insurance coverage and other provisions of the Affordable Care Act have sparked important changes that are facilitating comprehensive, high-quality care for people with substance use disorders. For example, the Affordable Care Act provided mandatory funding for Federally Qualified Health Centers (FQHCs) receiving grants under section 330 of the public health service act, including community health centers, migrant health centers, health care for the homeless health centers, and public housing primary care centers that is supporting the expansion of their activities and numbers of patients served.

These community health centers emphasize coordinated primary and preventive services that promote reductions in health disparities for low-income individuals, racial and ethnic minorities, rural communities, and other underserved populations. Two-thirds of health centers have been designated as PCMHs.^352^ PCMHs emphasize care, coordination, and communication to improve health care quality, lower health care costs, and enhance both the patient and provider experience.

Community health centers provide primary and preventive health services to medically underserved areas and populations and may offer behavioral and mental health and substance use services as appropriate to meet the health needs of the population served by the health center. As such, they are well-equipped to address co-occurring physical, mental, and substance use disorders, and provide substance misuse prevention, treatment, and RSS to patients. Because they provide services regardless of ability to pay and are required to offer services on a sliding scale fee, they are well-positioned to serve low-income and economically vulnerable patients.

An example of the important role FQHCs can play in improving access to treatment for substance use disorders is their efforts in providing buprenorphine maintenance treatment for opioid-dependent patients within primary care. In 2016, $94 million was awarded by HRSA to 271 health centers in 45 states, the District of Columbia, and Puerto Rico with a focus on augmenting capacity to treat opioid use disorders in vulnerable populations. FQHCs have access to 340B drug pricing, making the purchase of substance use disorder medications less costly and thus more accessible than for providers who cannot take advantage of this pricing.^353^ Recent services research indicates that such arrangements can achieve comparable outcomes to those achieved within the specialty addiction treatment sector.^354^

### Electronic Health Records and Health Information Technology

EHRs and health IT have the potential to support better coordination of services across primary care and specialty substance use disorder treatment, greater safety by reducing harmful drug-drug interactions, and improved monitoring of treatment outcomes and relapse risk in general health care.

Strong health IT systems improve the organization and usability of clinical data, thereby helping patients, health care professionals, and health system leaders coordinate care, promote shared decision-making, and engage in quality improvement efforts. These systems have the capacity to easily provide information in multiple languages and to put patients in touch with culturally appropriate providers through telehealth

“Meaningful use” rules from CMS now provide incentives for the use of certified health IT to facilitate care coordination. Medicare and Medicaid EHR Incentive Programs have thus far paid more than $34.5 billion in incentive payments for providers who adopt, implement, upgrade, and use certified EHR technology.^355^ These incentives have worked: The National Electronic Health Record Survey found that as of 2014, more than 80 percent of primary care physicians had adopted an EHR, and more than half were using all basic functions.^356^ These were the highest rates of any physician type using certified EHRs.

KEY TERMS

Meaningful Use. Using certified EHR technology to improve quality, safety, efficiency, and reduce health disparities; engage patients and family; improve care coordination and population and public health; and maintain privacy and security of patient health information.^2^

Health IT has shown benefits in improving care for patients with chronic conditions,^357^ and use is expected to greatly increase because of the Affordable Care Act and related incentives, such as grants supporting health center networks with the implementation and adoption of health IT.^358-361^ To further heighten uptake and implementation, CMS issued new rules to “ease the reporting burden for providers, support interoperability, and improve patient outcomes,” including giving states and providers more time to comply with regulations and focusing on health information interoperability between providers and patients.^335,362^ Additionally, CMS recently published its proposed rule on the Medicare Access and CHIP Reauthorization Act (MACRA) of 2015, providing incentives for using health IT to report quality measure results.

Health IT also holds great potential for improving services for individuals with substance misuse problems because they can provide up-to-date medical histories of patients to providers, and they can support care coordination by facilitating communications between primary and specialty care providers across health systems.^363^ Clinical decision support tools can also help support improvements in care and include clinical guidelines, diagnostic support, condition-specific order sets, computerized alerts and reminders to care providers as well as patients, focused patient data reports and summaries, documentation templates, and contextually relevant reference information, among others. For example, educational and training materials including clinical guidelines for physicians (e.g., Helping Patients Who Drink Too Much: A Clinician's Guide^364^), can be made available through EHRs. Many health systems have additional information on wikis for patients and providers. Most have or will have patient portal websites, which can provide patients access to health, mental health, and substance use self-assessments; computerized interventions for reducing alcohol or drug use, anger management, dealing with depression, and other problems; referral sources for smoking quit-lines and self-help groups; information on medications for substance use disorders; and general health information.

KEY TERMS

Clinical Decision Support. A system that provides health care professionals, staff, patients, or other individuals with knowledge and person-specific information, intelligently filtered or presented at appropriate times, to enhance health and health care.

Although research suggests that patients with substance use disorders are not using patient portals as much as individuals with other conditions,^365^ they have great potential for reaching patients.^366-368^ In particular, because they can be culturally relevant, these innovations may be helpful in providing substance use disorder services to individuals who do not have access to, or are hesitant to participate in, traditional services, or to augment those services, thereby helping to reduce health disparities.

To foster systems change, efforts are needed to increase adoption of EHR technology in substance use disorder and mental health treatment organizations. These programs currently lag and are likely to continue to lag behind the rest of medicine. It will be critical to facilitate the uptake of EHRs within the specialty substance use disorder treatment system, to implement common data standards to support interoperability across specialty substance use disorder treatment and mainstream health care, and to coordinate care across systems. The federal interagency Behavioral Health Coordinating Council recently created a quality metrics subcommittee tasked with ensuring that substance use and mental health performance and quality measures are consistently and appropriately included across payment systems of HHS, including diverse programs within CMS. The National Institute on Drug Abuse (NIDA) and NIAAA have developed common data elements for inclusion in EHRs, and SAMHSA supports the development of data standards for collecting behavioral health data in EHRs through the international standards development organization, Health Level 7, though none of these standards has been widely implemented to date.^364,369,370^

PDMPs are becoming an increasingly important health IT tool for preventing substance misuse and identifying patients with substance use disorders. As discussed above, PDMPs are state-run databases that collect prescribed and dispensed controlled prescriptions drug information and give providers and pharmacists access to information about a person's controlled substance prescription history. They are designed to help identify patients (as well as providers) who are misusing or diverting (i.e., channeling drugs into illegal use) these medications who would benefit from early interventions. This technology represents a promising state-level intervention for improving opioid prescribing, informing clinical practice, and protecting patients at risk in the midst of the ongoing opioid overdose epidemic. A number of states have passed legislation requiring prescribers to check their PDMP before prescribing controlled substances. Additional research is needed to identify best practices and policies to maximize the efficacy of these programs.

### Disease Registries

Databases related to specific diseases or combinations of diseases have long been used by health care professionals to manage chronic conditions such as diabetes or HIV/AIDS. Now these disease registries are being developed for substance use disorders, such as opioid use disorder.^371^ Although privacy concerns exist, disease registries can alert providers to the health care needs of those at risk because of substance misuse, including patients receiving opioids for chronic pain. Even low levels of alcohol and drug use are important factors in this population.^372^

### Prevention of Substance Misuse and Substance Use Disorders Through Public Health Approaches

Because substance use disorders often first come to light in the context of school, law enforcement, and employment, communities have many opportunities to expand the delivery of prevention and treatment services to include schools and school-based health care clinics, jails and prisons, and places of employment. Services provided in these settings can range from prevention education to SBIRT to treatment for substance use disorders. For example, law enforcement and emergency medical services in many communities are already collaborating in the distribution and administration of naloxone to prevent opioid overdose deaths.

These efforts require a public health approach and the development of a comprehensive community infrastructure, which in turn requires coordination across federal, state, local, and tribal agencies. A number of states are developing promising approaches to address substance use in their communities. One recent example is Minnesota's 2012 State Substance Abuse Strategy, which includes a comprehensive strategy focused on strengthening prevention; creating more opportunities for intervening before problems become severe; integrating the identification and treatment of substance use disorders into health care reform efforts; expanding support for recovery; interrupting the cycle of substance use, crime, and incarceration; reducing trafficking, production, and sale of illegal drugs; and measuring the impact of various interventions.^373^

Comprehensive Addiction and Recovery Act (CARA)

On July 22, 2016, President Obama signed the Comprehensive Addiction and Recovery Act (CARA), into law. CARA aims to address the national epidemic of opioid addiction by creating and expanding federal grant programs to:

- Temporarily expand eligibility to prescribe buprenorphine-based drugs for MAT for substance use disorders to qualifying nurse practitioners and physician assistants, through October 1, 2021;
- Expand access to opioid overdose reversal drugs, by supporting the purchase and distribution of such medications and training for first responders;
- Increase awareness and educate the public regarding the misuse of prescription opioids;
- Reauthorize the National All Schedules Prescription Electronic Reporting (NASPER) Act, which provides grants to states to support and improve interoperability of PDMPs;
- Authorize Medicare prescription drug plans to develop a safe prescribing and dispensing program for beneficiaries that are at risk of misuse or diversion of drugs that are frequently abused or diverted;
- Create a comprehensive program at U.S. Department of Justice to improve efforts by law enforcement and the criminal justice system to address substance use disorders; and
- Establish an HHS-led task force to consolidate federal best practices for pain management.

These measures are important steps for reducing the impact of prescription drug misuse on America's communities by preventing and responding to opioid addiction. However, given the large number of Americans with untreated or inadequately treated opioid use disorders and the current scarcity of treatment resources, there is concern that the lack of funding for the bill will prevent this new law from having a substantial impact on the nation's ongoing opioid epidemic.

The opioid guideline published by the Washington State Agency Medical Directors' Group is another useful example. This group is composed of medical directors from seven state agencies, including the Department of Labor and Industries, the Health Care Authority, the Board of Health, the Health Officer, the Department of Veterans Affairs, the Office of the Insurance Commissioner, and the Department of Corrections. In 2007, the group developed its first opioid prescribing guideline in collaboration with practicing physicians, with the latest update released in 2015.^374^ The guideline offers an approach to pain management that includes recommendations for appropriate opioid prescribing and management.

States' and localities' efforts to expand naloxone distribution provide another example of building a comprehensive, multipronged, community infrastructure. Many communities have recognized the need to make this potentially lifesaving medication more widely available. For example, community leaders in Wilkes County, North Carolina, implemented Project Lazarus, a model that expands access to naloxone for law enforcement, emergency services, education, and health services, and reduced the county overdose rate by half within a year. North Carolina also passed a law in 2013 that implemented standing orders, allowing naloxone to be dispensed from a pharmacy without a prescription.^375^

States have also expanded training on naloxone use for opioid users and their families and friends, as well as for a wide range of social service agency personnel. Federal partners have been instrumental in expanding access to naloxone training. HRSA established the Rural Opioid Overdose Reversal program in fiscal year 2015, awarding grants of $100,000 to 18 recipients representing 13 states to increase access to naloxone and train health care professionals and other social service personnel to administer the drug. In 2016, SAMHSA also provided $11,000,000 in funding to prevent prescription drug/opioid overdose-related deaths among individuals aged 18 or older by training first responders and other community stakeholders on prevention strategies.

A few states have passed legislation to make naloxone more readily available without a prescription if certain procedures are followed.^376,377^ As of July 2015, 30 states have passed laws to provide legal protection to physician prescribers and to bystanders (“Good Samaritans”) who administer naloxone when encountering an overdose situation.^378^ Additionally, 48 states allow pharmacists to enter into Collaborative Pharmacy Practice Agreements with prescribers, which allow naloxone to be dispensed to those who may be able to use it to save lives.^379^ For example, the Rhode Island Board of Pharmacy approved this type of agreement, which began in 2011 as a pilot program in five pharmacies. This program was expanded to all interested pharmacies in 2013 and formalized in regulation in 2014.^380,381^

States have also expanded naloxone coverage under Medicaid. The CDC reported more than 26,000 overdose reversals by lay people between 1996 and 2014, all using naloxone.^382^ Health systems are developing protocols to dispense naloxone through primary care providers, pharmacies, and emergency departments. The need to engage individuals in services to address their opioid use is a critical next step following an overdose reversal. This becomes increasingly challenging as naloxone kits are distributed widely, rather than when distribution is limited to health care and substance use disorder treatment providers. In 2013, the State of Vermont implemented an innovative treatment system with the goal of increasing access to opioid treatment throughout the state. This model, called the “Hub and Spoke” approach, met this need by providing physicians throughout the state with training and supports for providing evidence-based buprenorphine treatment.

The result has been:^383,384^

- An increase in the number of physicians providing buprenorphine treatment by over 40 percent;
- The transition of several hundred individuals served in traditional OTP programs to certified physicians in primary care settings;
- Better access throughout the state to opioid treatment due to the expansion of entry points, and physician/OTP coordination; and
- An increased integration of primary care and addiction treatment.

## Recommendations for Research

A key finding from this chapter is that the traditional separation of specialty addiction treatment from mainstream health care has created obstacles to successful care coordination. Research is needed in three main areas:

- Models of integration of substance use services within mainstream health care;
- Models of providing ongoing, chronic care within health care systems; and
- Models of care coordination between specialty treatment systems and mainstream health care.

In each of these areas, research is needed on the development of interventions and strategies for successfully implementing them. Outcomes for each model should include feasibility, substance use and other health outcomes, and cost.

Although a great deal of research has shown that integrating health care services has potential value both in terms of outcomes and cost, only a few models of integration have been empirically tested. Mechanisms through the Affordable Care Act make it possible to provide and test innovative structural and financing models for integration within mainstream health care. This research should cover the continuum of care, from prevention and early intervention to treatment and recovery, and will help health systems move forward with integration. This research should explore innovative delivery models including telemedicine and other health IT, as well as health or wellness coaching. Studies should focus on patient-centered approaches and should address appropriate interventions for individuals across race and ethnicity, culture, language, sex, sexual orientation, gender identity, disability, health literacy, and for those living in rural areas. So as not to limit health care systems to services for those with mild or moderate substance misuse problems and to offer support for individuals with severe problems who are not motivated to go to specialty substance use disorder treatment, it is also important to study how to implement medication and other evidence-based treatments across diverse health care systems.

This chapter pointed out that when substance use problems become severe, providing ongoing, chronic care is required, as is the case for many other diseases. Little research has studied chronic care models for the treatment of substance use disorders. Research is needed to develop and test innovative models of care coordination and their implementation. This research should use a more broadly defined workforce in both health care and substance use disorder treatment, develop models to share information electronically, and support coordination of care between health systems using health IT.

Finally, the chapter pointed out the gap in our understanding of how to implement models of care coordination between specialty addiction treatment organizations and social service systems, which provide important wrap-around services to substance use disorder patients. Many models are in existence, but have not been empirically tested. This area of research should involve institutions that provide services to individuals with serious co-occurring problems (specialty mental health agencies), individuals with legal problems (criminal justice agencies and drug courts), individuals with employment or other social issues, as well as the larger community, determining how to most effectively link each of these subpopulations with a recovery-oriented systems of care.

## References

1 World Health Organization. (2015). Health systems strengthening glossary, G-H. Health Systems.
2 HealthIT.gov. (2015). Meaningful use definition & objectives.
3 SAMHSA-HRSA Center for Integrated Health Solutions. (2016). What is integrated care?.
4 Institute of Medicine (IOM). (2013). Best care at lower cost: The path to continuously learning health care in America.
5 Puddy RW, Wilkins N. (2011). Understanding evidence Part 1: Best available research evidence. A guide to the continuum of evidence of effectiveness.
6 Larochelle MR, Liebschutz JM, Zhang F, Ross-Degnan D, Wharam JF. (2016). Opioid prescribing after nonfatal overdose and association with repeated overdose: A cohort study. Annals of Internal Medicine.
7 Binswanger IA, Stern MF, Deyo RA, Heagerty PJ, Cheadle A, Elmore JG, Koepsell TD. (2007). Release from prison—A high risk of death for former inmates. New England Journal of Medicine.
8 Baumohl J, Room R. (1987). Inebriety, doctors and the state: Alcoholism treatment institutions before 1940. Galanter M, editor. Recent Developments in Alcoholism.
9 Baumohl J, Jaffe JH. (2001). Treatment, history of, in the United States. Carson-DeSwitt R, editor. Encyclopedia of Drugs, Alcohol, and Addictive Behavior.
10 Weisner C, Morgan P. (1992). Rapid growth and bifurcation: Public and private alcohol treatment in the United States. Cure, care or Control: Alcoholism treatment in sixteen countries.
11 White WL. (1998). Slaying the dragon: The history of addiction treatment and recovery in America.
12 McLellan AT, Lewis DC, O'Brien CP, Kleber HD. (2000). Drug dependence, a chronic medical illness: Implications for treatment, insurance, and outcomes evaluation. JAMA.
13 Soderstrom CA, Smith GS, Dischinger PC, McDuff DR, Hebel JR, Gorelick DA, Read KM. (1997). Psychoactive substance use disorders among seriously injured trauma center patients. JAMA.
14 Wu L-T, Swartz MS, Wu Z, Mannelli P, Yang C, Blazer DG. (2012). Alcohol and drug use disorders among adults in emergency department settings in the United States. Annals of Emergency Medicine.
15 Brown RL, Leonard T, Saunders LA, Papasouliotis O. (1998). The prevalence and detection of substance use disorders among inpatients ages 18 to 49: An opportunity for prevention. Preventive Medicine.
16 Scott KM, Lim C, Al-Hamzawi A, Alonso J, Bruffaerts R, Caldas-de-Almeida JM, de Jonge P. (2016). Association of mental disorders with subsequent chronic physical conditions: World mental health surveys from 17 countries. JAMA Psychiatry.
17 Parish CL, Pereyra MR, Pollack HA, Cardenas G, Castellon PC, Abel SN, Metsch LR. (2015). Screening for substance misuse in the dental care setting: Findings from a nationally representative survey of dentists. Addiction.
18 Denisco RC, Kenna GA, O'Neil MG, Kulich RJ, Moore PA, Kane WT, Katz NP. (2011). Prevention of prescription opioid abuse: The role of the dentist. The Journal of the American Dental Association.
19 Krause M, Vainio L, Zwetchkenbaum S, Inglehart MR. (2010). Dental education about patients with special needs: A survey of US and Canadian dental schools. Journal of Dental Education.
20 O'Connor PG, Nyquist JG, McLellan AT. (2011). Integrating addiction medicine into graduate medical education in primary care: The time has come. Annals of Internal Medicine.
21 McLellan AT, Meyers K. (2004). Contemporary addiction treatment: A review of systems problems for adults and adolescents. Biological Psychiatry.
22 Miller NS, Sheppard LM, Colenda CC, Magen J. (2001). Why physicians are unprepared to treat patients who have alcohol-and drug-related disorders. Academic Medicine.
23 D'Amico EJ, Paddock SM, Burnam A, Kung F-Y. (2005). Identification of and guidance for problem drinking by general medical providers: Results from a national survey. Medical Care.
24 Knudsen HK, Abraham AJ, Oser CB. (2011). Barriers to the implementation of medication-assisted treatment for substance use disorders: the importance of funding policies and medical infrastructure. Eval Program Plann.
25 Mattick RP, Breen C, Kimber J, Davoli M. (2014). Buprenorphine maintenance versus placebo or methadone maintenance for opioid dependence. Cochrane Database of Systematic Reviews.
26 MacDonald K, Lamb K, Thomas ML, Khentigan W. (2016). Buprenorphine maintenance treatment of opiate dependence: Correlations between prescriber beliefs and practices. Substance Use & Misuse.
27 Mattick RP, Breen C, Kimber J, Davoli M. (2009). Methadone maintenance therapy versus no opioid replacement therapy for opioid dependence. Cochrane Database Syst Rev.
28 Nunes EV, Krupitsky E, Ling W, Zummo J, Memisoglu A, Silverman BL, Gastfriend DR. (2015). Treating opioid dependence with injectable extended-release naltrexone (XR- NTX): Who will respond?. Journal of Addiction Medicine.
29 Institute of Medicine Division of Mental Health and Behavioral Medicine. (1990). Broadening the base of treatment for alcohol problems.
30 Gerstein DR, Lewin LS. (1990). Treating drug problems. New England Journal of Medicine.
31 Institute of Medicine Committee on Quality of Health Care in America. (2001). Crossing the quality chasm: A new health system for the 21st century.
32 Institute of Medicine, & Committee on Crossing the Quality Chasm. (2006). Improving the quality of health care for mental and substance-use conditions.
33 Congressional Budget Office. Insurance coverage provisions of the Affordable Care Act: CBOS March 2015 baseline.
34 U.S. Department of Health and Human Services. (2016). Health insurance coverage and the affordable care act, 2010–2016.
35 Mark TL, Wier LM, Malone K, Penne M, Cowell AJ. (2015). National estimates of behavioral health conditions and their treatment among adults newly insured under the ACA. Psychiatric Services.
36 Artiga S, Stephens J, Damico A. (2015). The impact of the coverage gap in states not expanding Medicaid by race and ethnicity. The Henry J. Kaiser Family Foundation.
37 Garfield R, Damico A, Cox C. (2015). New estimates of eligibility for ACA coverage among the uninsured.
38 Crowley RA, Kirschner N. (2015). The integration of care for mental health, substance abuse, and other behavioral health conditions into primary care: Executive summary of an American College of Physicians position paper. Annals of Internal Medicine.
39 Centers for Medicare & Medicaid Services. (2015). Screening, brief intervention, and referral to treatment (SBIRT) services.
40 Centers for Medicare & Medicaid Services. (2011). Decision memo for screening and behavioral counseling interventions in primary care to reduce alcohol misuse (CAG-00427N).
41 U.S. Department of Labor. (2013). FAQs about Affordable Care Act implementation part XII.
42 Jonas DE, Garbutt JC, Amick HR. (2012). Behavioral counseling after screening for alcohol misuse in primary care: A systematic review and meta-analysis for the U.S. Preventive Services Task Force. Annals of Internal Medicine.
43 Moyer VA. (2013). Screening and behavioral counseling interventions in primary care to reduce alcohol misuse: U.S. Preventive Services Task Force recommendation statement. Annals of Internal Medicine.
44 Maciosek MV, Coffield AB, Edwards NM, Flottemesch TJ, Goodman MJ, Solberg LI. (2006). Priorities among effective clinical preventive services: Results of a systematic review and analysis. American Journal of Preventive Medicine.
45 Solberg LI, Maciosek MV, Edwards NM. (2008). Primary care intervention to reduce alcohol misuse: Ranking its health impact and cost effectiveness. American Journal of Preventive Medicine.
46 Roy-Byrne P, Bumgardner K, Krupski A, Dunn C, Ries R, Donovan D, Graves MC. (2014). Brief intervention for problem drug use in safety-net primary care settings: A randomized clinical trial. JAMA.
47 Saitz R, Palfai TP, Cheng DM, Alford DP, Bernstein JA, Lloyd-Travaglini CA, Samet JH. (2014). Screening and brief intervention for drug use in primary care: The ASPIRE randomized clinical trial. JAMA.
48 Gelberg L, Andersen RM, Afifi AA, Leake BD, Arangua L, Vahidi M, Fleming MF. (2015). Project QUIT (Quit Using Drugs Intervention Trial): A randomized controlled trial of a primary care-based multi-component brief intervention to reduce risky drug use. Addiction.
49 Heinzerling KG, Ober AJ, Lamp K, De Vries D, Watkins KE. (2016). SUMMIT: Procedures for medication-assisted treatment of alcohol or opioid dependence in primary care.
50 Shapiro B, Coffa D, McCance-Katz EF. (2013). A primary care approach to substance misuse. American Family Physician.
51 Manchikanti L, Helm S, Fellows B, Janata JW, Pampati V, Grider JS, Boswell MV. (2012). Opioid epidemic in the United States. Pain Physician.
52 Weisner CM, Campbell CI, Ray GT, Saunders K, Merrill JO, Banta-Green C, Boudreau D. (2009). Trends in prescribed opioid therapy for non-cancer pain for individuals with prior substance use disorders. Pain.
53 Campbell CI, Weisner C, LeResche L, Ray GT, Saunders K, Sullivan MD, Boudreau D. (2010). Age and gender trends in long-term opioid analgesic use for noncancer pain. American Journal of Public Health.
54 Office of the Assistant Secretary for Planning and Evaluation. (2015). Opioid abuse in the US and HHS actions to address opioid-drug related overdoses and deaths.
55 Dowell D, Haegerich TM, C R. (2016). CDC guideline for prescribing opioids for chronic pain - United States. MMWR.
56 Office of the Assistant Secretary for Health. (2016). National pain strategy: A comprehensive population health-level strategy for pain.
57 National Heroin Task Force. (2015). National heroin task force final report and recommendations.
58 Muhuri PK, Gfroerer JC, Davies MC. (2013). Associations of nonmedical pain reliever use and initiation of heroin use in the United States. CBHSQ Data Review.
59 Cicero TJ, Ellis MS, Surratt HL, Kurtz SP. (2014). The changing face of heroin use in the United States: A retrospective analysis of the past 50 years. JAMA Psychiatry.
60 Substance Abuse and Mental Health Services Administration. (2013). SAMHSA Opioid overdose prevention toolkit.
61 Mueller SR, Walley AY, Calcaterra SL, Glanz JM, Binswanger IA. (2015). A review of opioid overdose prevention and naloxone prescribing: Implications for translating community programming into clinical practice. Substance Abuse.
62 Binswanger IA, Koester S, Mueller SR, Gardner EM, Goddard K, Glanz JM. (2015). Overdose education and naloxone for patients prescribed opioids in primary care: A qualitative study of primary care staff. Journal of General Internal Medicine.
63 Compton WM, Blanco C, Wargo EM. (2015). Integrating addiction services into general medicine. JAMA.
64 Mertens JR, Lu YW, Parthasarathy S, Moore C, Weisner CM. (2003). Medical and psychiatric conditions of alcohol and drug treatment patients in an HMO: Comparison with matched controls. Archives of Internal Medicine.
65 Grant BF, Dawson DA. (1999). Alcohol and drug use, abuse, and dependence: classification, prevalence, and comorbidity. McCrady BS, Epstein EE, editors. Addictions: A comprehensive guidebook.
66 Weisner C, Mertens J, Parthasarathy S, Moore C, Lu Y. (2001). Integrating primary medical care with addiction treatment: A randomized controlled trial. JAMA.
67 Stein MD. (1999). Medical consequences of substance abuse. Psychiatric Clinics of North America.
68 Wachino V. (2015). Re: New service delivery opportunities for individuals with a substance use disorder.
69 Mertens JR, Weisner C, Ray GT, Fireman B, Walsh K. (2005). Hazardous drinkers and drug users in HMO primary care: Prevalence, medical conditions, and costs. Alcoholism: Clinical and Experimental Research.
70 Lange RA, Hillis LD. (2001). Cardiovascular complications of cocaine use. New England Journal of Medicine.
71 Rubin RB, Neugarten J. (1992). Medical complications of cocaine: Changes in pattern of use and spectrum of complications. Journal of Toxicology: Clinical Toxicology.
72 Ashton CH. (2001). Pharmacology and effects of cannabis: A brief review. British Journal of Psychiatry.
73 Hall W, Solowij N. (1998). Adverse effects of cannabis. The Lancet.
74 Volkow ND, Baler RD, Compton WM, Weiss SRB. (2014). Adverse health effects of marijuana use. New England Journal of Medicine.
75 Rehm J, Mathers C, Popova S, Thavorncharoensap M, Teerawattananon Y, Patra J. (2009). Global burden of disease and injury and economic cost attributable to alcohol use and alcohol-use disorders. The Lancet.
76 Middleton Fillmore K, Chikritzhs T, Stockwell T, Bostrom A, Pascal R. (2009). Alcohol use and prostate cancer: A meta-analysis. Molecular Nutrition & Food Research.
77 Bagnardi V, Rota M, Botteri E, Tramacere I, Islami F, Fedirko V, Pasquali E. (2015). Alcohol consumption and site-specific cancer risk: A comprehensive dose–response meta-analysis. British Journal of Cancer.
78 Jung S, Wang M, Anderson K, Baglietto L, Bergkvist L, Bernstein L, Eliassen AH. (2015). Alcohol consumption and breast cancer risk by estrogen receptor status: In a pooled analysis of 20 studies. International Journal of Epidemiology.
79 May PA, Gossage JP, Kalberg WO, Robinson LK, Buckley D, Manning M, Hoyme HE. (2009). Prevalence and epidemiologic characteristics of FASD from various research methods with an emphasis on recent in-school studies. Developmental Disabilities Research Review.
80 May PA, Baete A, Russo J, Elliott AJ, Blankenship J, Kalberg WO, Hoyme HE. (2014). Prevalence and characteristics of fetal alcohol spectrum disorders. Pediatrics.
81 U.S. National Library of Medicine. (2015). Neonatal abstinence syndrome.
82 Patrick S, Davis M, Lehmann C, Cooper W. (2015). Increasing incidence and geographic distribution of neonatal abstinence syndrome: United States 2009 to 2012. Journal of Perinatology.
83 National Institute on Drug Abuse. (2015). Dramatic increases in maternal opioid use and neonatal abstinence syndrome.
84 Floyd RL, Jack BW, Cefalo R, Atrash H, Mahoney J, Herron A, Sokol RJ. (2008). The clinical content of preconception care: Alcohol, tobacco, and illicit drug exposures. American Journal of Obstetrics and Gynecology.
85 Aarons GA, Brown SA, Coe MT, Myers MG, Garland AF, Ezzet-Lofstram R, Hough RL. (1999). Adolescent alcohol and drug abuse and health. Journal of Adolescent Health.
86 Arria AM, Dohey MA, Mezzich AC, Bukstein OG, Van Thiel DH. (1995). Self- reported health problems and physical symptomatology in adolescent alcohol abusers. Journal of Adolescent Health.
87 Clark DB, Lynch KG, Donovan JE, Block GD. (2001). Health problems in adolescents with alcohol use disorders: Self-report, liver injury, and physical examination findings and correlates. Alcoholism: Clinical and Experimental Research.
88 Wachino V, Hyde PS. (2015). Coverage of behavioral health services for youth with substance use disorders.
89 Shrier LA, Harris SK, Sternberg M, Beardslee WR. (2001). Associations of depression, self-esteem, and substance use with sexual risk among adolescents. Preventive Medicine.
90 Schwartz RH, Luxenberg MG, Hoffmann NG. (1991). “Crack” use by American middle- class adolescent polydrug abusers. Journal of Pediatrics.
91 Mertens JR, Flisher AJ, Fleming MF, Weisner CM. (2007). Medical conditions of adolescents in alcohol and drug treatment: Comparison with matched controls. Journal of Adolescent Health.
92 Grella CE, Hser YI, Joshi V, Rounds-Bryant J. (2001). Drug treatment outcomes for adolescents with comorbid mental and substance use disorders. Journal of Nervous and Mental Disease.
93 Sterling S, Weisner C. (2005). Chemical dependency and psychiatric services for adolescents in private managed care: Implications for outcomes. Alcoholism: Clinical and Experimental Research.
94 Dunne EM, Hearn LE, Rose JJ, Latimer WW. (2014). ADHD as a risk factor for early onset and heightened adult problem severity of illicit substance use: An accelerated gateway model. Addictive Behaviors.
95 Groenman AP, Oosterlaan J, Rommelse N, Franke B, Roeyers H, Oades RD, Faraone SV. (2013). Substance use disorders in adolescents with attention deficit hyperactivity disorder: A 4-year follow-up study. Addiction.
96 Levy S, Katusic SK, Colligan RC, Weaver AL, Killian JM, Voigt RG, Barbaresi WJ. (2014). Childhood ADHD and risk for substance dependence in adulthood: A longitudinal, population-based study. PLOS One.
97 Wilens TE, Spencer TJ. (2010). Understanding attention-deficit/hyperactivity disorder from childhood to adulthood. Postgraduate Medicine.
98 Zulauf CA, Sprich SE, Safren SA, Wilens TE. (2014). The complicated relationship between attention deficit/hyperactivity disorder and substance use disorders. Current Psychiatry Reports.
99 Elkins IJ, McGue M, Iacono WG. (2007). Prospective effects of attention-deficit/hyperactivity disorder, conduct disorder, and sex on adolescent substance use and abuse. Archives of General Psychiatry.
100 Degenhardt L, Coffey C, Romaniuk H, Swift W, Carlin JB, Hall WD, Patton GC. (2013). The persistence of the association between adolescent cannabis use and common mental disorders into young adulthood. Addiction.
101 Armstrong TD, Costello EJ. (2002). Community studies on adolescent substance use, abuse, or dependence and psychiatric comorbidity. Journal of Consulting and Clinical Psychology.
102 Maslowsky J, Schulenberg JE, Zucker RA. (2014). Influence of conduct problems and depressive symptomatology on adolescent substance use: Developmentally proximal versus distal effects. Developmental Psychology.
103 Conway KP, Compton W, Stinson FS, Grant BF. (2006). Lifetime comorbidity of DSM-IV mood and anxiety disorders and specific drug use disorders: Results from the National Epidemiologic Survey on Alcohol and Related Conditions. The Journal of Clinical Psychiatry.
104 Ammon L, Sterling S, Mertens J, Weisner C. (2005). Adolescents in private chemical dependency programs: Who are most at risk for HIV?. Journal of Substance Abuse Treatment.
105 Madan A, Beech DJ, Flint L. (2001). Drugs, guns, and kids: The association between substance use and injury caused by interpersonal violence. Journal of Pediatric Surgery.
106 Williams AF, Tefft BC. (2014). Characteristics of teens-with-teens fatal crashes in the United States, 2005-2010. Journal of Safety Research.
107 Fals-Stewart W, Golden J, Schumacher JA. (2003). Intimate partner violence and substance use: A longitudinal day-to-day examination. Addictive Behaviors.
108 Hingson R, Heeren T, Levenson S, Jamanka A, Voas R. (2002). Age of drinking onset, driving after drinking, and involvement in alcohol related motor-vehicle crashes. Accident Analysis & Prevention.
109 Hingson RW, Zha W. (2009). Age of drinking onset, alcohol use disorders, frequent heavy drinking, and unintentionally injuring oneself and others after drinking. Pediatrics.
110 Whiteford HA, Degenhardt L, Rehm J, Baxter AJ, Ferrari AJ, Erskine HE, Vos T. (2013). Global burden of disease attributable to mental and substance use disorders: Findings from the Global Burden of Disease Study 2010. The Lancet.
111 McLellan AT, Starrels JL, Tai B, Gordon AJ, Brown R, Ghitza U, Horton T. (2014). Can substance use disorders be managed using the chronic care model? Review and recommendations from a NIDA Consensus Group. Public Health Reviews.
112 Chi FW, Parthasarathy S, Mertens JR, Weisner CM. (2011). Continuing care and long-term substance use outcomes in managed care: Early evidence for a primary care based model. Psychiatric Services.
113 Parthasarathy S, Chi FW, Mertens JR, Weisner C. (2012). The role of continuing care on 9-year cost trajectories of patients with intakes into an outpatient alcohol and drug treatment program. Medical Care.
114 Saitz R, Horton NJ, Larson MJ, Winter M, Samet JH. (2005). Primary medical care and reductions in addiction severity: A prospective cohort study. Addiction.
115 Samet JH, Friedmann P, Saitz R. (2001). Benefits of linking primary medical care and substance abuse services: Patient, provider, and societal perspectives. Archives of Internal Medicine.
116 Saitz R, Cheng DM, Winter M, Kim TW, Meli SM, Allensworth-Davies D, Samet JH. (2013). Chronic care management for dependence on alcohol and other drugs: The AHEAD randomized trial. JAMA.
117 Samet JH, Larson MJ, Horton NJ, Doyle K, Winter M, Saitz R. (2003). Linking alcohol-and drug-dependent adults to primary medical care: A randomized controlled trial of a multi-disciplinary health intervention in a detoxification unit. Addiction.
118 Watkins K, Pincus HA, Tanielian TL, Lloyd J. (2003). Using the chronic care model to improve treatment of alcohol use disorders in primary care settings. Journal of Studies on Alcohol.
119 Park TW, Cheng DM, Samet JH, Winter MR, Saitz R. (2015). Chronic care management for substance dependence in primary care among patients with co-occurring disorders. Psychiatric Services.
120 Mertens JR, Flisher AJ, Satre DD, Weisner CM. (2008). The role of medical conditions and primary care services in 5-year substance use outcomes among chemical dependency treatment patients. Drug and Alcohol Dependence.
121 Willenbring ML, Olson DH. (1999). A randomized trial of integrated outpatient treatment for medically ill alcoholic men. Archives of Internal Medicine.
122 O'Donnell A, Anderson P, Newbury-Birch D, Schulte B, Schmidt C, Reimer J, Kaner E. (2014). The impact of brief alcohol interventions in primary healthcare: A systematic review of reviews. Alcohol and Alcoholism.
123 Bien TH, Miller WR, Tonigan JS. (1993). Brief interventions for alcohol problems: A review. Addiction.
124 Fleming MF, Barry KL, Manwell LB, Johnson K, London R. (1997). Brief physician advice for problem alcohol drinkers: A randomized controlled trial in community-based primary care practices. JAMA.
125 Rose HL, Miller PM, Nemeth LS, Jenkins RG, Nietert PJ, Wessell AM, Ornstein S. (2008). Alcohol screening and brief counseling in a primary care hypertensive population: A quality improvement intervention. Addiction.
126 Oslin DW, Lynch KG, Maisto SA, Lantinga LJ, McKay JR, Possemato K, Wierzbicki M. (2014). A randomized clinical trial of alcohol care management delivered in Department of Veterans Affairs primary care clinics versus specialty addiction treatment. Journal of General Internal Medicine.
127 England MJ, Butler AS, Gonzalez ML. (2015). Psychosocial interventions for mental and substance use disorders: A framework for establishing evidence-based standards.
128 Arthur MW, Blitz C. (2000). Bridging the gap between science and practice in drug abuse prevention through needs assessment and strategic community planning. Journal of Community Psychology.
129 Arthur MW, Briney JS, Hawkins JD, Abbott RD, Brooke-Weiss BL, Catalano RF. (2007). Measuring risk and protection in communities using the Communities That Care youth survey. Evaluation and Program Planning.
130 Mrazek PB, Biglan A, Hawkins JD. (2004). Community-monitoring systems: Tracking and improving the well-being of America's children and adolescents.
131 McLellan AT, Kemp J, Brooks A, Carise D. (2008). Improving public addiction treatment through performance contracting: The Delaware experiment. Health Policy.
132 Vandrey R, Stitzer ML, Acquavita SP, Quinn-Stabile P. (2011). Pay-for-performance in a community substance abuse clinic. Journal of Substance Abuse Treatment.
133 Center for Substance Abuse Treatment. (2005). Substance abuse treatment for persons with co-occurring disorders.
134 Friedmann PD, D'Aunno TA, Jin L, Alexander JA. (2000). Medical and psychosocial services in drug abuse treatment: Do stronger linkages promote client utilization?. Health Services Research.
135 Asarnow JR, Rozenman M, Wiblin J, Zeltzer L. (2015). Integrated medical-behavioral care compared with usual primary care for child and adolescent behavioral health: A meta- analysis. JAMA.
136 Heath B, Wise Romero P, Reynolds KA. (2013). A standard framework for levels of integrated healthcare.
137 Lo CC, Cheng TC. (2011). Racial/ethnic differences in access to substance abuse treatment. Journal of Health Care for the Poor and Underserved.
138 Saloner B, Le Cook B. (2013). Blacks and Hispanics are less likely than whites to complete addiction treatment, largely due to socioeconomic factors. Health Affairs.
139 Satre DD, Campbell CI, Gordon NP, Weisner C. (2010). Ethnic disparities in accessing treatment for depression and substance use disorders in an integrated health plan. The International Journal of Psychiatry in Medicine.
140 Mulia N, Tam TW, Schmidt LA. (2014). Disparities in the use and quality of alcohol treatment services and some proposed solutions to narrow the gap. Psychiatric Services.
141 Wen H, Druss BG, Cummings JR. (2015). Effect of Medicaid expansions on health insurance coverage and access to care among low-income adults with behavioral health conditions. Health Services Research.
142 Artiga S, Damico A, Garfield R. (2015). Estimates of eligibility for ACA coverage among the uninsured by race and ethnicity.
143 Vestal C. (2015). States gear up to help Medicaid enrollees beat addictions.
144 Substance Abuse and Mental Health Services Administration. (2013). Behavioral health treatment needs assessment toolkit for states.
145 Floyd RL, Sobell M, Velasquez MM, Ingersoll K, Nettleman M, Sobell L, Nagaraja J. (2007). Preventing alcohol-exposed pregnancies: A randomized controlled trial. American Journal of Preventive Medicine.
146 Hanson JD, Pourier S. (2015). The Oglala Sioux Tribe CHOICES program: Modifying an existing alcohol-exposed pregnancy intervention for use in an American Indian community. International Journal of Environmental Research and Public Health.
147 Nayak MB, Korcha RA, Kaskutas LA, Avalos LA. (2014). Feasibility and acceptability of a novel, computerized screening and brief intervention (SBI) for alcohol and sweetened beverage use in pregnancy. BMC Pregnancy & Childbirth.
148 Lee CS, López SR, Colby SM, Rohsenow D, Hernández L, Borrelli B, Caetano R. (2013). Culturally adapted motivational interviewing for Latino heavy drinkers: Results from a randomized clinical trial. Journal of Ethnicity in Substance Abuse.
149 Chan Y-F, Lu S-E, Howe B, Tieben H, Hoeft T, Unützer J. (2016). Screening and follow- up monitoring for substance use in primary care: An exploration of rural–urban variations. Journal of General Internal Medicine.
150 Campbell CI, Chi F, Sterling S, Kohn C, Weisner C. (2009). Self-initiated tobacco cessation and substance use outcomes among adolescents entering substance use treatment in a managed care organization. Addictive Behaviors.
151 Sterling S, Chi F, Campbell C, Weisner C. (2009). Three-year chemical dependency and mental health treatment outcomes among adolescents: The role of continuing care. Alcoholism: Clinical and Experimental Research.
152 Chi FW, Kaskutas LA, Sterling S, Campbell CI, Weisner C. (2009). Twelve-step affiliation and 3-year substance use outcomes among adolescents: Social support and religious service attendance as potential mediators. Addiction.
153 Evans E, Spear SE, Huang Y-C, Hser Y-I. (2006). Outcomes of drug and alcohol treatment programs among American Indians in California. American journal of public health.
154 Dickerson DL, Spear S, Marinelli-Casey P, Rawson R, Li L, Hser Y-I. (2010). American Indians/Alaska Natives and substance abuse treatment outcomes: Positive signs and continuing challenges. Journal of Addictive Diseases.
155 Satre DD, Chi FW, Mertens JR, Weisner CM. (2012). Effects of age and life transitions on alcohol and drug treatment outcome over nine years. Journal of Studies on Alcohol and Drugs.
156 Field C, Caetano R. (2010). The role of ethnic matching between patient and provider on the effectiveness of brief alcohol interventions with Hispanics. Alcoholism: Clinical and Experimental Research.
157 Ruglass LM, Hien DA, Hu M-C, Campbell AN, Caldeira NA, Miele GM, Chang DF. (2014). Racial/ethnic match and treatment outcomes for women with PTSD and substance use disorders receiving community-based treatment. Community Mental Health Journal.
158 Doty MM. (2003). Hispanic patients' double burden: Lack of health insurance and limited English.
159 Petry NM. (2003). A comparison of African American and non-Hispanic Caucasian cocaine- abusing outpatients. Drug and Alcohol Dependence.
160 Bay Area Addiction and Research and Treatment, Inc. F.3d.
161 Ondersma SJ, Beatty JR, Svikis DS, Strickler RC, Tzilos GK, Chang G, Sokol RJ. (2015). Computer-delivered screening and brief intervention for alcohol use in pregnancy: A pilot randomized trial. Alcoholism: Clinical and Experimental Research.
162 Belenko S, Patapis P, French MT. (2005). Economic benefits of drug treatment: A critical review of the evidence for policy makers.
163 Cartwright WS. (1998). Cost-benefit and cost-effectiveness analysis of drug abuse treatment services. Evaluation Review.
164 Cartwright WS. (2000). Cost-benefit analysis of drug treatment services: Review of the literature. Journal of Mental Health Policy and Economics.
165 Harwood HJ, Malhotra D, Villarivera C, Liu C, Chong U, Gilani J. (2002). Cost effectiveness and cost benefit analysis of substance abuse treatment: A literature review.
166 Levit KR, Kassed CA, Coffey RM, Mark TL, McKusick DR, King E, Stranges E. (2008). Projections of national expenditures for mental health services and substance abuse treatment, 2004–2014.
167 Substance Abuse and Mental Health Services Administration. (2016). Behavioral health spending and use accounts, 1986–2014.
168 Sacks JJ, Gonzales KR, Bouchery EE, Tomedi LE, Brewer RD. (2015). 2010 national and state costs of excessive alcohol consumption. American Journal of Preventive Medicine.
169 National Drug Intelligence Center. (2011). National drug threat assessment.
170 Ettner SL, Huang D, Evans E, Ash DR, Hardy M, Jourabchi M, Hser YI. (2006). Benefit-cost in the California treatment outcome project: Does substance abuse treatment “pay for itself”?. Health Services Research.
171 Godfrey C, Stewart D, Gossop M. (2004). Economic analysis of costs and consequences of the treatment of drug misuse: 2-year outcome data from the National Treatment Outcome Research Study (NTORS). Addiction.
172 Humphreys K, Wagner TH, Gage M. (2011). If substance use disorder treatment more than offsets its costs, why don't more medical centers want to provide it?. Journal of Substance Abuse Treatment.
173 National Council for Behavioral Health. (2014). The business case for effective substance use disorder treatment.
174 Basu A, Paltiel AD, Pollack HA. (2008). Social costs of robbery and the cost-effectiveness of substance abuse treatment. Health Economics.
175 Fleming MF, Mundt MP, French MT, Manwell LB, Stauffacher EA, Barry KL. (2002). Brief physician advice for problem drinkers: Long-term efficacy and benefit-cost analysis. Alcoholism: Clinical and Experimental Research.
176 Maheswaran R, Beevers M, Beevers DG. (1992). Effectiveness of advice to reduce alcohol consumption in hypertensive patients. Hypertension.
177 Parthasarathy S, Mertens J, Moore C, Weisner C. (2003). Utilization and cost impact of integrating substance abuse treatment and primary care. Medical Care.
178 Stewart SH, Latham PK, Miller PM, Randall P, Anton RF. (2008). Blood pressure reduction during treatment for alcohol dependence: Results from the Combining Medications and Behavioral Interventions for Alcoholism (COMBINE) study. Addiction.
179 National Institute on Drug Abuse. (2012). Principles of drug addiction treatment: A research-based guide.
180 Peters RH, Wexler HK, Lurigio AJ. (2015). Co-occurring substance use and mental disorders in the criminal justice system: A new frontier of clinical practice and research. Psychiatric Rehabilitation Journal.
181 Zarkin GA, Cowell AJ, Hicks KA, Mills MJ, Belenko S, Dunlap LJ, Keyes V. (2015). Lifetime benefits and costs of diverting substance-abusing offenders from state prison. Crime & Delinquency.
182 McCollister KE, French MT, Prendergast M, Wexler H, Sacks S, Hall E. (2003). Is in- prison treatment enough? A cost-effectiveness analysis of prison-based treatment and aftercare services for substance-abusing offenders. Law & Policy.
183 Traube DE. (2012). The missing link to child safety, permanency, and well-being: Addressing substance misuse in child welfare. Social Work Research.
184 Berger LM, Slack KS, Waldfogel J, Bruch SK. (2010). Caseworker-perceived caregiver substance abuse and child protective services outcomes. Child Maltreatment.
185 Aarons GA, Brown SA, Hough RL, Garland AF, Wood PA. (2001). Prevalence of adolescent substance use disorders across five sectors of care. Journal of the American Academy of Child & Adolescent Psychiatry.
186 Institute of Medicine. (2013). Substance use disorders in the US armed forces.
187 Harwood HJ, Zhang Y, Dall TM, Olaiya ST, Fagan NK. (2009). Economic implications of reduced binge drinking among the military health system's TRICARE Prime plan beneficiaries. Military Medicine.
188 Estee S, Nordlund DJ. (2003). Washington State supplemental security income (SSI) cost offset pilot project: 2002 progress report.
189 Wickizer TM, Krupski A, Stark KD, Mancuso D, Campbell K. (2006). The effect of substance abuse treatment on Medicaid expenditures among general assistance welfare clients in Washington State. Milbank Quarterly.
190 Wickizer TM, Mancuso D, Huber A. (2012). Evaluation of an innovative Medicaid health policy initiative to expand substance abuse treatment in Washington State. Medical Care Research and Review.
191 Zarkin GA, Dunlap LJ, Homsi G. (2004). The substance abuse services cost analysis program (SASCAP): A new method for estimating drug treatment services costs. Evaluation and Program Planning.
192 Flynn PM, Broome KM, Beaston-Blaakman A, Knight DK, Horgan CM, Donald SS. (2009). Treatment cost analysis tool (TCAT) for estimating costs of outpatient treatment services. Drug and Alcohol Dependence.
193 Bray JW, Zarkin GA, Hinde JM, Mills MJ. (2012). Costs of alcohol screening and brief intervention in medical settings: A review of the literature. Journal of Studies on Alcohol and Drugs.
194 Zarkin G, Bray J, Hinde J, Saitz R. (2015). Costs of screening and brief intervention for illicit drug use in primary care settings. Journal of Studies on Alcohol and Drugs.
195 Hartung DM, McCarty D, Fu R, Wiest K, Chalk M, Gastfriend DR. (2014). Extended- release naltrexone for alcohol and opioid dependence: A meta-analysis of healthcare utilization studies. Journal of Substance Abuse Treatment.
196 Lynch FL, McCarty D, Mertens J, Perrin NA, Green CA, Parthasarathy S, Pating D. (2014). Costs of care for persons with opioid dependence in commercial integrated health systems. Addiction Science & Clinical Practice.
197 McCarty D, Perrin NA, Green CA, Polen MR, Leo MC, Lynch F. (2010). Methadone maintenance and the cost and utilization of health care among individuals dependent on opioids in a commercial health plan. Drug and Alcohol Dependence.
198 Zarkin GA, Bray JW, Aldridge A, Mitra D, Mills MJ, Couper DJ, Cisler RA. (2008). Cost and cost-effectiveness of the COMBINE study in alcohol-dependent patients. Archives of General Psychiatry.
199 Drummond MF, Sculpher MJ, Torrance GW, O'Brien BJ, Stoddart GL. (2005). Methods for the economic evaluation of health care programmes.
200 Alterman AI, O'Brien CP, McLellan AT, August DS, Snider EC, Droba M, Schrade FX. (1994). Effectiveness and costs of inpatient versus day hospital cocaine rehabilitation. Journal of Nervous and Mental Disease.
201 Daley M, Love CT, Shepard DS, Peterson CB, White KL, Hall FB. (2004). Cost-effectiveness of Connecticut's in-prison substance abuse treatment. Journal of Offender Rehabilitation.
202 Jofre-Bonet M, Sindelar JL, Petrakis IL, Nich C, Frankforter T, Rounsaville BJ, Carroll KM. (2004). Cost effectiveness of disulfiram: Treating cocaine use in methadone- maintained patients. Journal of Substance Abuse Treatment.
203 Masson CL, Barnett PG, Sees KL, Delucchi KL, Rosen A, Wong W, Hall SM. (2004). Cost and cost-effectiveness of standard methadone maintenance treatment compared to enriched 180-day methadone detoxification. Addiction.
204 McCollister KE, French MT, Pendergast ML, Hall E, Sacks S. (2004). Long-term cost effectiveness of addiction treatment for criminal offenders: Evaluating treatment history and reincarceration five years post-parole. Justice Quarterly.
205 Mojtabai R, Zivin JG. (2003). Effectiveness and cost-effectiveness of four treatment modalities for substance disorders: A propensity score analysis. Health Services Research.
206 Pettinati HM, Meyers K, Evans BD, Ruetsch CR, Kaplan FN, Jensen JM, Hadley TR. (1999). Inpatient alcohol treatment in a private healthcare setting: Which patients benefit and at what cost?. The American Journal on Addictions.
207 Schinka JA, Francis E, Hughes P, LaLone L, Flynn C. (1998). Comparative outcomes and costs of inpatient care and supportive housing for substance-dependent veterans. Psychiatric Services.
208 Shepard DS, Larson MJ, Hoffmann NG. (1999). Cost-effectiveness of substance abuse services: Implications for public policy. Psychiatric Clinics of North America.
209 Sindelar JL, Jofre-Bonet M, French MT, McLellan AT. (2004). Cost-effectiveness analysis of addiction treatment: Paradoxes of multiple outcomes. Drug and Alcohol Dependence.
210 Drug Rehab Centers. Self pay drug treatment programs.
211 Mark TL, Yee T, Levit KR, Camacho-Cook J, Cutler E, Carroll CD. (2016). Insurance financing increased for mental health conditions but not for substance use disorders, 1986–2014. Health Affairs.
212 Smith JC, Medalia C, U.S. Census Bureau. (2015). Health insurance coverage in the United States: 2014.
213 American Psychiatric Association. (2000). Diagnostic and statistical manual of mental disorders (DSM- IV).
214 Woodward A. (2016). Special analysis based on 2013 National Survey on Drug Use and Health data.
215 Jensen GA, Morrisey MA. (1991). Employer-sponsored insurance coverage for alcohol and drug abuse treatment, 1988. Inquiry.
216 Rouse BA. (1995). Substance abuse and mental health statistics sourcebook.
217 Shepard D, Daley M, Ritter G, Hodgkin D, Beinecke R. (2002). Managed care and the quality of substance abuse treatment. Journal of Mental Health Policy and Economics.
218 Rosenbach M, Lake T. (2003). Mental health and substance abuse parity in Vermont: What did we learn?.
219 Statista. Health insurance status distribution of the total U.S. population in 2014.
220 U.S. Government Accountability Office. Health > 20. State Medicaid sources of funds.
221 The Henry J. Kaiser Family Foundation. (2016). Federal and state share of Medicaid spending.
222 Wachino V. (2015). Coverage of housing-related activities and services for individuals with disabilities CMCS Informational Bulletin.
223 Dey J, Rosenoff E, West K, Ali MLS, McClellan C, Mutter R, Woodward A. (2016). ASPE Issue brief: Benefits of Medicaid expansion for behavioral health.
224 Centers for Medicare & Medicaid Services. (2016). Medicare enrollment dashboard.
225 Bouchery EE, Harwood HJ, Dilonardo J, Vandivort-Warren R. (2012). Type of health insurance and the substance abuse treatment gap. Journal of Substance Abuse Treatment.
226 Center for Behavioral Health Statistics and Quality. Analysis of the 2013 National Survey of Drug Use and Health.
227 Jackson H, Mandell K, Johnson K, Chatterjee D, Vanness DJ. (2015). Cost effectiveness of injectable extended release naltrexone compared to methadone maintenance and buprenorphine maintenance treatment for opioid dependence. Substance Abuse.
228 Polsky D, Glick HA, Yang J, Subramaniam GA, Poole SA, Woody GE. (2010). Cost- effectiveness of extended buprenorphine-naloxone treatment for opioid-dependent youth: Data from a randomized trial. Addiction.
229 Schackman BR, Leff JA, Polsky D, Moore BA, Fiellin DA. (2012). Cost-effectiveness of long-term outpatient buprenorphine-naloxone treatment for opioid dependence in primary care. Journal of General Internal Medicine.
230 Angus C, Latimer N, Preston L, Li J, Purshouse R. (2014). What are the implications for policy makers? A systematic review of the cost-effectiveness of screening and brief interventions for alcohol misuse in primary care. Frontiers.
231 Miller T, Hendrie D. (2008). Substance abuse prevention dollars and cents: A cost-benefit analysis.
232 Washington State Institute for Public Policy. (2015). Benefit-cost results.
233 Substance Abuse and Mental Health Services Administration. (2015). Substance abuse and mental health block grants.
234 Office of National Drug Control Policy. (2015). Drug-free communities support program.
235 Lee S, Aos S, Drake E, Pennucci A, Miller M, Anderson L. (2012). Return on investment: Evidence-based options to improve statewide outcomes.
236 GrantSpace. (2015). What is a health conversion foundation? How can I learn more about them?. Knowledge Base.
237 Isaacs SL, Beatrice DF, Carr W. (1997). Health care conversion foundations: A status report. Health Affairs.
238 Cantor J, Mikkelsen L, Simons B, Waters R. (2013). How can we pay for a healthy population? Innovative new ways to redirect funds to community prevention.
239 Lunder EK, Liu EC. (2012). 501(c)(3) Hospitals: Proposed IRS rules under § 9007 of the Affordable Care Act.
240 Rosenbaum S, Byrnes M, Riek AM. (2013). Hospital tax-exempt policy: A comparison of schedule H and state community benefit reporting systems. Frontiers in Public Health Services and Systems Research.
241 Durch JS, Bailey LA, Stoto MA. (1997). Improving health in a community: A role for performance monitoring.
242 Huang J, Walton K, Gerzoff RB, King BA, Chaloupka FJ, Centers for Disease Control and Prevention. (2015). State tobacco control program spending—United States, 2011. MMWR.
243 Mid-America Regional Council & Homelessness Task Force of Greater Kansas City. (2014). Investment plan to address the needs of at-risk children and youth in greater Kansas City.
244 Pérez A. (2008). Earmarking state taxes.
245 Massachusetts Department of Public Health Bureau of Community Health and Prevention. (2015). The Massachusetts prevention and wellness trust fund 2014 legislative report.
246 Congressional Budget Office. (2016). Federal subsidies for health insurance coverage for people under age 65: 2016 to 2026.
247 Humphreys K, Frank RG. (2014). The Affordable Care Act will revolutionize care for substance use disorders in the United States. Addiction.
248 Buck JA. (2011). The looming expansion and transformation of public substance abuse treatment under the Affordable Care Act. Health Affairs.
249 Horgan CM, Stewart MT, Reif S, Garnick DW, Hodgkin D, Merrick EL, Quinn AE. (2015). Behavioral health services in the changing landscape of private health plans. Psychiatric Services.
250 D'Aunno T, Friedmann PD, Chen Q, Wilson DM. (2015). Integration of substance abuse treatment organizations into accountable care organizations: Results from a national survey. Journal of Health Politics, Policy and Law.
251 Weisner CM, Chi FW, Lu Y, Ross TB, Wood SB, Hinman A, Sterling SA. (2016). Examination of the effects of an intervention aiming to link patients receiving addiction treatment with health care: The LINKAGE clinical trial. JAMA Psychiatry.
252 Molfenter TD. (2014). Addiction treatment centers' progress in preparing for health care reform. Journal of Substance Abuse Treatment.
253 Andrews C, Abraham A, Grogan C, Pollack H, Bersamira C, Humphreys K, Friedmann P. (2015). Despite resources from the ACA, most states do little to help addiction treatment programs implement health care reform. Health Affairs.
254 Molfenter T, Capoccia VA, Boyle MG, Sherbeck CK. (2012). The readiness of addiction treatment agencies for health care reform. Substance Abuse Treatment, Prevention, and Policy.
255 Knudsen HK, Ducharme LJ, Roman PM. (2006). Early adoption of buprenorphine in substance abuse treatment centers: Data from the private and public sectors. Journal of Substance Abuse Treatment.
256 Wachino V. (2016). RE: Availability of HITECH administrative matching funds to help professionals and hospitals eligible for Medicaid EHR incentive payments connect to other Medicaid providers.
257 Corredoira R, Kimberly J. (2006). Industry evolution through consolidation: Implications for addiction treatment. Journal of Substance Abuse Treatment.
258 D'Aunno T. (2006). The role of organization and management in substance abuse treatment: Review and roadmap. Journal of Substance Abuse Treatment.
259 Knott AM, Corredoira R, Kimberly J. (2008). Improving consistency and quality of service delivery: Implications for the addiction treatment field. Journal of Substance Abuse Treatment.
260 Mark TL, Kassed CA, Vandivort-Warren R, Levit KR, Kranzler HR. (2009). Alcohol and opioid dependence medications: Prescription trends, overall and by physician specialty. Drug and Alcohol Dependence.
261 Horgan CM, Reif S, Hodgkin D, Garnick DW, Merrick EL. (2008). Availability of addiction medications in private health plans. Journal of Substance Abuse Treatment.
262 National Treatment Center Study. (2011). Barriers to the adoption of pharmacotherapies in publicly funded substance abuse treatment: Policy barriers and access to physicians.
263 Knudsen HK, Abraham AJ, Roman PM. (2011). Adoption and implementation of medications in addiction treatment programs. Journal of Addiction Medicine.
264 Knudsen HK, Ducharme LJ, Roman PM. (2007). The adoption of medications in substance abuse treatment: Associations with organizational characteristics and technology clusters. Drug and Alcohol Dependence.
265 Fuller BE, Rieckmann T, McCarty D, Smith KW, Levine H. (2005). Adoption of naltrexone to treat alcohol dependence. Journal of Substance Abuse Treatment.
266 Heinrich CJ, Hill CJ. (2008). Role of state policies in the adoption of naltrexone for substance abuse treatment. Health Services Research.
267 Aletraris L, Roman P. (2015). Adoption of injectable naltrexone in U.S. substance use disorder treatment programs. Journal of Studies on Alcohol and Drugs.
268 Andrews CM, D'Aunno TA, Pollack HA, Friedmann PD. (2014). Adoption of evidence- based clinical innovations: The case of buprenorphine use by opioid treatment programs. Medical Care Research and Review.
269 Stein BD, Pacula RL, Gordon AJ, Burns RM, Leslie DL, Sorbero MJ, Dick AW. (2015). Where is buprenorphine dispensed to treat opioid use disorders? The role of private offices, opioid treatment programs, and substance abuse treatment facilities in urban and rural counties. Milbank Quarterly.
270 (2016). Medication assisted treatment for opioid use disorders. Fed. Reg.
271 Assistant Secretary for Public Affairs (ASPA). (2010). Preventive services covered under the Affordable Care Act.
272 Kaner E, Bland M, Cassidy P, Coulton S, Dale V, Deluca P, Drummond C. (2013). Effectiveness of screening and brief alcohol intervention in primary care (SIPS trial): Pragmatic cluster randomised controlled trial. BMJ.
273 van Beurden I, Anderson P, Akkermans RP, Grol RP, Wensing M, Laurant MG. (2012). Involvement of general practitioners in managing alcohol problems: A randomized controlled trial of a tailored improvement programme. Addiction.
274 Williams EC, Johnson ML, Lapham GT, Caldeiro RM, Chew L, Fletcher GS, Bradley KA. (2011). Strategies to implement alcohol screening and brief intervention in primary care settings: A structured literature review. Psychology of Addictive Behaviors.
275 Williams EC, Rubinsky AD, Chavez LJ, Lapham GT, Rittmueller SE, Achtmeyer CE, Bradley KA. (2014). An early evaluation of implementation of brief intervention for unhealthy alcohol use in the U.S. Veterans Health Administration. Addiction.
276 Barry KL, Blow FC, Willenbring M, McCormick R, Brockmann LM, Visnic S. (2004). Use of alcohol screening and brief interventions in primary care settings: Implementation and barriers. Substance Abuse.
277 Gassman RA. (2003). Medical specialization, profession, and mediating beliefs that predict stated likelihood of alcohol screening and brief intervention: Targeting educational interventions. Substance Abuse.
278 Fitzgerald N, Platt L, Heywood S, McCambridge J. (2015). Large-scale implementation of alcohol brief interventions in new settings in Scotland: A qualitative interview study of a national programme. BMC Public Health.
279 Ozer EM, Adams SH, Gardner LR, Mailloux DE, Wibbelsman CJ, Irwin CE. (2004). Provider self-efficacy and the screening of adolescents for risky health behaviors. Journal of Adolescent Health.
280 McKnight-Eily L, Liu R, Brewer Y, Kanny RD, Lu H, Denny CH, Centers for Disease Control and Prevention. (2014). Vital signs: Communication between health professionals and their patients about alcohol use - 44 states and the District of Columbia, 2011. MMWR.
281 Garnick DW, Horgan CM, Merrick EL, Hoyt A. (2007). Identification and treatment of mental and substance use conditions: Health plans strategies. Medical Care.
282 Sterling SA, Kline-Simon AH, Wibbelsman CJ, Wong AO, Weisner CM. (2012). Screening for adolescent alcohol and drug use in pediatric health-care settings: Predictors and implications for practice and policy. Addiction Science and Clinical Practice.
283 Moyer VA. (2014). Primary care behavioral interventions to reduce illicit drug and nonmedical pharmaceutical use in children and adolescents: U.S. Preventive Services Task Force recommendation statement. Annals of Internal Medicine.
284 Levy SJ, Williams JF, Committee on Substance Use and Prevention. (2016). Substance use screening, brief intervention, and referral to treatment. Pediatrics.
285 Substance Abuse and Mental Health Administration. (2016). Screening, brief intervention, and referral to treatment (SBIRT).
286 National Research Council and Institute of Medicine. (2009). Preventing mental, emotional, and behavioral disorders among young people: Progress and possibilities.
287 American Academy of Pediatrics Division of Child Health Research. (1998). 45% of fellows routinely screen for alcohol use. AAP News.
288 Bethell C, Klein J, Peck C. (2001). Assessing health system provision of adolescent preventive services: The Young Adult Health Care Survey. Medical Care.
289 Hassan A, Harris SK, Sherritt L, Van Hook S, Brooks T, Carey P, Knight JR. (2009). Primary care follow-up plans for adolescents with substance use problems. Pediatrics.
290 Wilson CR, Sherritt L, Gates E, Knight JR. (2004). Are clinical impressions of adolescent substance use accurate?. Pediatrics.
291 Sterling S, Kline-Simon AH, Satre DD, Jones A, Mertens J, Wong A, Weisner C. (2015). Implementation of screening, brief intervention, and referral to treatment for adolescents in pediatric primary care: A cluster randomized trial. JAMA Pediatrics.
292 Madras BK, Compton WM, Avula D, Stegbauer T, Stein JB, Clark HW. (2009). Screening, brief interventions, referral to treatment (SBIRT) for illicit drug and alcohol use at multiple healthcare sites: Comparison at intake and 6 months later. Drug and Alcohol Dependence.
293 Babor TE, Higgins-Biddle J, Dauser D, Higgins P, Burleson JA. (2005). Alcohol screening and brief intervention in primary care settings: Implementation models and predictors. Journal of Studies on Alcohol and Drugs.
294 Babor TF, Higgins-Biddle JC, Dauser D, Burleson JA, Zarkin GA, Bray J. (2006). Brief interventions for at-risk drinking: Patient outcomes and cost-effectiveness in managed care organizations. Alcohol and Alcoholism.
295 Cutrona SL, Choudhry NK, Stedman M, Servi A, Liberman JN, Brennan T, Shrank WH. (2010). Physician effectiveness in interventions to improve cardiovascular medication adherence: A systematic review. Journal of General Internal Medicine.
296 Georgeu D, Colvin CJ, Lewin S, Fairall L, Bachmann MO, Uebel K, Bateman ED. (2012). Implementing nurse-initiated and managed antiretroviral treatment (NIMART) in South Africa: A qualitative process evaluation of the STRETCH trial. Implementation Science.
297 Rahm AK, Boggs JM, Martin C, Price DW, Beck A, Backer TE, Dearing JW. (2015). Facilitators and barriers to implementing screening, brief intervention, and referral to treatment (SBIRT) in primary care in integrated health care settings. Substance Abuse.
298 Substance Abuse and Mental Health Services Administration. (2013). Systems-level implementation of screening, brief intervention, and referral to treatment.
299 Bradley KA, Williams EC, Achtmeyer CE, Volpp B, Collins BJ, Kivlahan DR. (2006). Implementation of evidence-based alcohol screening in the Veterans Health Administration. The American Journal of Managed Care.
300 Lapham GT, Achtmeyer CE, Williams EC, Hawkins EJ, Kivlahan DR, Bradley KA. (2012). Increased documented brief alcohol interventions with a performance measure and electronic decision support. Medical Care.
301 Mertens JR, Chi FW, Weisner CM, Satre DD, Ross TB, Allen S, Sterling SA. (2015). Physician versus non-physician delivery of alcohol screening, brief intervention and referral to treatment in adult primary care: The ADVISe cluster randomized controlled implementation trial. Addiction Science & Clinical Practice.
302 Williams EC, Lapham G, Achtmeyer CE, Volpp B, Kivlahan DR, Bradley KA. (2010). Use of an electronic clinical reminder for brief alcohol counseling is associated with resolution of unhealthy alcohol use at follow-up screening. Journal of General Internal Medicine.
303 Seale JP, Johnson JA, Clark DC, Shellenberger S, Pusser AT, Dhabliwala J, Clemow D. (2015). A multisite initiative to increase the use of alcohol screening and brief intervention through resident training and clinic systems changes. Academic Medicine.
304 Seale JP, Shellenberger S, Tillery WK, Boltri J, Vogel R, Barton B, McCauley M. (2005). Implementing alcohol screening and intervention in a family medicine residency clinic. Substance Abuse.
305 Williams EC, Achtmeyer CE, Young JP, Rittmueller SE, Ludman EJ, Lapham GT, Bradley KA. (2016). Local implementation of alcohol screening and brief intervention at five Veterans Health Administration primary care clinics: Perspectives of clinical and administrative staff. Journal of Substance Abuse Treatment.
306 Hoge MA, Stuart GW, Morris J, Flaherty MT, Paris M, Goplerud E. (2013). Mental health and addiction workforce development: Federal leadership is needed to address the growing crisis. Health Affairs.
307 Substance Abuse and Mental Health Services Administration. (2013). Report to Congress on the nation's substance abuse and mental health workforce issues.
308 Bureau of Labor Statistics. Occupational outlook handbook 2010-11.
309 Health Resources and Services Administration. Shortage areas.
310 Corwin E. (2016). Shortage of addiction counselors further strained by opioid epidemic. Shots: Health news from NPR.
311 Eby LT, Burk H, Maher CP. (2010). How serious of a problem is staff turnover in substance abuse treatment? A longitudinal study of actual turnover. Journal of Substance Abuse Treatment.
312 Peikes DN, Reid RJ, Day TJ, Cornwell DD, Dale SB, Baron RJ, Shapiro RJ. (2014). Staffing patterns of primary care practices in the comprehensive primary care initiative. The Annals of Family Medicine.
313 Hall J, Cohen DJ, Davis M, Gunn R, Blount A, Pollack DA, Miller BF. (2015). Preparing the workforce for behavioral health and primary care integration. Journal of the American Board of Family Medicine.
314 Miller BF, Brown Levey SM, Payne-Murphy JC, Kwan BM. (2014). Outlining the scope of behavioral health practice in integrated primary care: Dispelling the myth of the one- trick mental health pony. Families, Systems, & Health.
315 Urada D, Schaper E, Alvarez L, Reilly C, Dawar M, Field R, Rawson RA. (2012). Perceptions of mental health and substance use disorder services integration among the workforce in primary care settings. Journal of Psychoactive Drugs.
316 (2002). Haack MR, Adger JH, editors. Strategic plan for interdisciplinary faculty development: Arming the nation's health professional workforce for a new approach to substance use disorders.
317 Isaacson JH, Fleming M, Kraus M, Kahn R, Mundt M. (2000). A national survey of training in substance use disorders in residency programs. Journal of Studies on Alcohol and Drugs.
318 The Annapolis Coalition on the Behavioral Health Workforce. (2007). An action plan for behavioral health workforce development: A framework for discussion.
319 Kerwin ME, Walker-Smith K, Kirby KC. (2006). Comparative analysis of state requirements for the training of substance abuse and mental health counselors. Journal of Substance Abuse Treatment.
320 Dilonardo J. (2011). Workforce issues related to: Bi-directional physical and behavioral healthcare integration specifically substance use disorders and primary care Issue Brief #4.
321 Dilonardo J. (2011). Workforce issues related to: Physical and behavioral healthcare integration: Specifically substance use disorders and primary care.
322 International Certification & Reciprocity Consortium. Prevention specialist (PS): A credential for your career & your community.
323 National Association of State Alcohol and Drug Abuse Directors (NASADAD), Northrop Grumman Information Technology. (2005). A national review of state alcohol and drug treatment programs and certification standards for substance abuse counselors and prevention professionals.
324 Health Resources and Services Administration (HRSA). (2015). FY 2016 annual performance report.
325 HealthIT.gov. (2016). Standards and certification regulations: 2015 edition final rule.
326 Clark T, Eadie J, Kreiner P, Strickler G. (2012). Prescription drug monitoring programs: An assessment of the evidence for best practices.
327 U.S. Department of Justice Drug Enforcement Administration Office of Diversion Control. (2011). State prescription drug monitoring programs.
328 Substance Abuse and Mental Health Services Administration. (2013). Medicaid handbook: Interface with behavioral health services.
329 Medicaid.gov. Benefits.
330 Mann C. (2012). Policy considerations for integrated care models.
331 Centers for Medicare & Medicaid Services. Medicaid innovation accelerator program (IAP).
332 Centers for Medicare & Medicaid Services. (2012). Health homes (Section 2703) frequently asked questions.
333 Nardone M, Paradise J. (2014). Medicaid health homes: A profile of newer programs Issue Brief.
334 Health Home Information Resource Center. (2015). Medicaid health homes: SPA overview.
335 Centers for Medicare & Medicaid Services. (2015). State innovation models initiative: General information. CMS.gov.
336 Ormond B, Richardson E, Spillman B, Feder J. (2014). Health homes in Medicaid: The promise and the challenge.
337 Spillman BC, Ormond BA, Richardson E. (2012). Evaluation of the Medicaid health home option for beneficiaries with chronic conditions: Final annual report - base year.
338 Phillips RL, Han M, Petterson SM, Makaroff LA, Liaw WR. (2014). Cost, utilization, and quality of care: An evaluation of Illinois' Medicaid primary care case management program. Annals of Family Medicine.
339 Baird M, Blount A, Brungardt S, Dickinson P, Dietrich A, Epperly T, Korsen N. (2014). Joint principles: Integrating behavioral health care into the patient-centered medical home. The Annals of Family Medicine.
340 Substance Abuse and Mental Health Services Administration. (2014). Advancing behavioral health integration within NCQA recognized patient-centered medical homes.
341 Andrews C, Grogan C, Brennan M, Pollack HA. (2015). Lessons From Medicaid's divergent paths on mental health and addiction services. Health Affairs.
342 Berwick DM, Nolan TW, Whittington J. (2008). The triple aim: Care, health, and cost. Health Affairs.
343 Hacker K, Walker DK. (2013). Achieving population health in accountable care organizations. American Journal of Public Health.
344 Alley DE, Asomugha CN, Conway PH, Sanghavi DM. (2016). Accountable health communities — Addressing social needs through Medicare and Medicaid. New England Journal of Medicine.
345 National Academy for State Health Policy (NASHP). (2012). State ‘accountable care’ activity map.
346 Purington K, Gauthier A, Patel S, Miller C. (2011). On the road to better value: State roles in promoting accountable care organizations.
347 Rodin D, Silow-Carroll S. (2013). Medicaid payment and delivery reform in Colorado: ACOs at the regional level.
348 Schoenherr KE, Van Citters AD, Carluzzo KL, Bergquist S, Fisher ES, Lewis VA. (2013). Establishing a coalition to pursue accountable care in the safety net: A case study of the FQHC urban health network.
349 Association of State and Territorial Health Officials. (2015). Community-clinical linkages to improve hypertension identification, management, and control.
350 Institute of Medicine, Roundtable on Population Health Improvement, Board on Population Health and Public Health Practice. (2014). Population health implications of the Affordable Care Act: Workshop summary.
351 Oregon Health Authority Office of Health Analytics. (2015). Oregon's health system transformation: 2014 final report.
352 Health Resources and Services Administration. What is a health center?.
353 Health Resources and Services Administration (HRSA). (2016). HHS awards $94 million to health centers to help treat the prescription opioid abuse and heroin epidemic in America.
354 Haddad MS, Zelenev A, Altice FL. (2013). Integrating buprenorphine maintenance therapy into federally qualified health centers: Real-world substance abuse treatment outcomes. Drug and Alcohol Dependence.
355 Centers for Medicare & Medicaid Services. (2016). April 2016 EHR incentive program.
356 Heisey-Grove D, Patel V. (2015). Any, certified, and basic: Quantifying physician EHR adoption through 2014.
357 Leveille SG, Huang A, Tsai SB, Allen M, Weingart SN, Iezzoni LI. (2009). Health coaching via an internet portal for primary care patients with chronic conditions: A randomized controlled trial. Medical Care.
358 Health Resources and Services Administration. (2012). Affordable Care Act helps expand the use of health information technology.
359 Centers for Medicare & Medicaid Services. (2014). Eligible professional meaningful use table of contents core and menu set objectives.
360 Office of the National Coordinator for Health Information Technology. (2013). Meaningful use. HealthIT.gov.
361 Terry NP. (2013). Meaningful adoption: What we know or think we know about the financing, effectiveness, quality, and safety of electronic medical records. Journal of Legal Medicine.
362 Centers for Medicare & Medicaid Services. (2015). Fact sheet: Electronic health record incentive program and health IT certification program final rule.
363 Ghitza UE, Tai B. (2014). Challenges and opportunities for integrating preventive substance-use-care services in primary care through the Affordable Care Act. Journal of Health Care for the Poor and Underserved.
364 National Institute on Alcohol Abuse and Alcoholism. (2005). Helping patients who drink too much: A clinician's guide.
365 Shimada SL, Brandt CA, Feng H, McInnes DK, Rao SR, Rothendler JA, Houston TK. (2014). Personal health record reach in the Veterans Health Administration: A cross- sectional analysis. Journal of Medical Internet Research.
366 Goldzweig CL, Orshansky G, Paige NM, Towfigh AA, Haggstrom DA, Miake-Lye I, Shekelle PG. (2013). Electronic patient portals: evidence on health outcomes, satisfaction, efficiency, and attitudes: A systematic review. Annals of Internal Medicine.
367 Weingart SN, Rind D, Tofias Z, Sands DZ. (2006). Who uses the patient internet portal? The PatientSite experience. Journal of the American Medical Informatics Association.
368 Ancker JS, Barrón Y, Rockoff ML, Hauser D, Pichardo M, Szerencsy A, Calman N. (2011). Use of an electronic patient portal among disadvantaged populations. Journal of General Internal Medicine.
369 Ghitza UE, Gore-Langton RE, Lindblad R, Shide D, Subramaniam G, Tai B. (2013). Common data elements for substance use disorders in electronic health records: The NIDA clinical trials network experience. Addiction.
370 Tai B, McLellan AT. (2012). Integrating information on substance use disorders into electronic health record systems. Journal of Substance Abuse Treatment.
371 Ray GT, Bahorik A, Weisner C, Wakim P, VanHelhuisen P, Campbell CI. Development of a prescription opioid registry in an integrated health system: Characteristics of prescription opioid use.
372 Campbell CI, Kline-Simon AH, Von Korff M, Saunders KW, Weisner C. Alcohol and drug use and aberrant drug-related behavior among patients on chronic opioid therapy.
373 Minnesota Department of Human Services. (2012). Minnesota state substance abuse strategy.
374 Agency Medical Directors' Group (AMDG). (2015). Interagency guideline on prescribing opioids for pain.
375 (2013). Session Law 2013-23, Bill No. 20, General Assembly of North Carolina.
376 Humphreys K. (2015). An overdose antidote goes mainstream. Health Affairs.
377 Join Together Staff. (2015). CVS will sell naloxone without prescription in 14 states.
378 Davis C. (2015). Addressing legal barriers to naloxone access.
379 American Pharmacists Association. (2013). Collaborative practice agreements vary among the states.
380 Centers for Disease Control Prevention. (2013). Acetyl fentanyl overdose fatalities—Rhode Island, March-May 2013. MMWR.
381 State of Rhode Island and Providence Plantations Department of Health. (2014). Rules and regulations pertaining to opioid overdose prevention.
382 Wheeler E, Jones TS, Gilbert MK, Davidson PJ, Centers for Disease Control and Prevention. (2015). Opioid overdose prevention programs providing naloxone to laypersons—United States, 2014. MMWR.
383 Vermont Agency of Human Services. (2012). Integrated treatment continuum for substance use dependence “Hub/Spoke” Initiative—Phase 1: Opiate dependence.
384 American Association for the Treatment of Opioid Dependence, Inc. F3 VT's Hub and Spoke model for opioid addiction.

i The World Health Organization defines a health care system as (1) all the activities whose primary purpose is to promote, restore, and/or maintain health, and (2) the people, institutions, and resources, arranged together in accordance with established policies, to improve the health of the population they serve.^1^ Health care systems may provide a wide range of clinical services, from primary through subspecialty care and be delivered in offices, clinics, and hospitals. They can be run by private, government, non-profit, or for-profit agencies and organizations.