# CHAPTER 4 EARLY INTERVENTION, TREATMENT, AND MANAGEMENT OF SUBSTANCE USE DISORDERS

## Chapter 4 Preview

A substance use disorder is a medical illness characterized by clinically significant impairments in health, social function, and voluntary control over substance use.^2^ Substance use disorders range in severity, duration, and complexity from mild to severe. In 2015, 20.8 million people aged 12 or older met criteria for a substance use disorder. While historically the great majority of treatment has occurred in specialty substance use disorder treatment programs with little involvement by primary or general health care, a shift is occurring toward the delivery of treatment services in general health care practice. For those with mild to moderate substance use disorders, treatment through the general health care system may be sufficient, while those with severe substance use disorders (addiction) may require specialty treatment.

FOR MORE ON THIS TOPIC

See Chapter 6 - Health Care Systems and Substance Use Disorders.

The good news is that a spectrum of effective strategies and services are available to identify, treat, and manage substance use problems and substance use disorders. Research shows that the most effective way to help someone with a substance use problem who may be at risk for developing a substance use disorder is to intervene early, before the condition can progress. With this recognition, screening for substance misuse is increasingly being provided in general health care settings, so that emerging problems can be detected and early intervention provided if necessary. The addition of services to address substance use problems and disorders in mainstream health care has extended the continuum of care, and includes a range of effective, evidence-based medications, behavioral therapies, and supportive services. However, a number of barriers have limited the widespread adoption of these services, including lack of resources, insufficient training, and workforce shortages.^5^ This is particularly true for the treatment of those with co-occurring substance use and physical or mental disorders.^6,7^

This chapter provides an overview of the scientific evidence supporting the effectiveness of treatment interventions, therapies, services, and medications available to identify, treat, and manage substance use problems and disorders.

KEY FINDINGS^*^ * The Centers for Disease Control and Prevention (CDC) summarizes strength of evidence as: “Well-supported”: when evidence is derived from multiple controlled trials or large-scale population studies; “Supported”: when evidence is derived from rigorous but fewer or smaller trials; and “Promising”: when evidence is derived from a practical or clinical sense and is widely practiced.^8^

- Well-supported scientific evidence shows that substance use disorders can be effectively treated, with recurrence rates no higher than those for other chronic illnesses such as diabetes, asthma, and hypertension. With comprehensive continuing care, recovery is now an achievable outcome.
- Only about 1 in 10 people with a substance use disorder receive any type of specialty treatment. The great majority of treatment has occurred in specialty substance use disorder treatment programs with little involvement by primary or general health care. However, a shift is occurring to mainstream the delivery of early intervention and treatment services into general health care practice.
- Well-supported scientific evidence shows that medications can be effective in treating serious substance use disorders, but they are under-used. The U.S. Food and Drug Administration (FDA) has approved three medications to treat alcohol use disorders and three others to treat opioid use disorders. However, an insufficient number of existing treatment programs or practicing physicians offer these medications. To date, no FDA-approved medications are available to treat marijuana, cocaine, methamphetamine, or other substance use disorders, with the exception of the medications previously noted for alcohol and opioid use disorders.
- Supported scientific evidence indicates that substance misuse and substance use disorders can be reliably and easily identified through screening and that less severe forms of these conditions often respond to brief physician advice and other types of brief interventions. Well-supported scientific evidence shows that these brief interventions work with mild severity alcohol use disorders, but only promising evidence suggests that they are effective with drug use disorders.
- Well-supported scientific evidence shows that treatment for substance use disorders—including inpatient, residential, and outpatient—are cost-effective compared with no treatment.
- The primary goals and general management methods of treatment for substance use disorders are the same as those for the treatment of other chronic illnesses. The goals of treatment are to reduce key symptoms to non-problematic levels and improve health and functional status; this is equally true for those with co-occurring substance use disorders and other psychiatric disorders. Key components of care are medications, behavioral therapies, and recovery support services (RSS).
- Well-supported scientific evidence shows that behavioral therapies can be effective in treating substance use disorders, but most evidence-based behavioral therapies are often implemented with limited fidelity and are under-used. Treatments using these evidence-based practices have shown better results than non-evidence-based treatments and services.
- Promising scientific evidence suggests that several electronic technologies, like the adoption of electronic health records (EHRs) and the use of telehealth, could improve access, engagement, monitoring, and continuing supportive care of those with substance use disorders.

## Continuum of Treatment Services

Substance use disorders typically emerge during adolescence and often (but not always) progress in severity and complexity with continued substance misuse.^9,10^ Currently, substance use disorders are classified diagnostically into three severity categories: mild, moderate, and severe.^2^

Substance use disorder treatment is designed to help individuals stop or reduce harmful substance misuse, improve their health and social function, and manage their risk for relapse. In this regard, substance use disorder treatment is effective and has a positive economic impact. Research shows that treatment also improves individuals' productivity,^11^ health,^11,12^ and overall quality of life.^13-15^ In addition, studies show that every dollar spent on substance use disorder treatment saves $4 in health care costs and $7 in criminal justice costs.^11^

KEY TERMS

Substance Use Disorder Treatment. A service or set of services that may include medication, counseling, and other supportive services designed to enable an individual to reduce or eliminate alcohol and/or other drug use, address associated physical or mental health problems, and restore the patient to maximum functional ability.^3^

Continuum of Care. An integrated system of care that guides and tracks a person over time through a comprehensive array of health services appropriate to the individual's need. A continuum of care may include prevention, early intervention, treatment, continuing care, and recovery support.^4^

Mild substance use disorders can be identified quickly and reliably in many medical and social settings. These common but less severe disorders often respond to brief motivational interventions and/or supportive monitoring, referred to as guided self-change.^16^ In contrast, severe, complex, and chronic substance use disorders often require specialty substance use disorder treatment and continued post-treatment support to achieve full remission and recovery. To address the spectrum of substance use problems and disorders, a continuum of care provides individuals an array of service options based on need, including prevention, early intervention, treatment, and recovery support (Figure 4.1). Traditionally, the vast majority of treatment for substance use disorders has been provided in specialty substance use disorder treatment programs, and these programs vary substantially in their clinical objectives and in the frequency, intensity, and setting of care delivery.

Figure 4.1 Substance Use Status and Substance Use Care Continuum

Horizontal arrow below Substance Use Status Continuum and above Substance use Care Continuum.

This chapter describes the early intervention and treatment components of the continuum of care, the major behavioral, pharmacological, and service components of care, services available, and emerging treatment technologies:

- Early Intervention, for addressing substance misuse problems or mild disorders and helping to prevent more severe substance use disorders.
- Treatment engagement and harm reduction interventions, for individuals who have a substance use disorder but who may not be ready to enter treatment, help engage individuals in treatment and reduce the risks and harms associated with substance misuse.
- Substance use disorder treatment, an individualized set of evidence-based clinical services designed to improve health and function, including medications and behavioral therapies.
- Emerging treatment technologies are increasingly being used to support the assessment, treatment, and maintenance of continuing contact with individuals with substance use disorders.

## Early Intervention: Identifying and Engaging Individuals At Risk for Substance Misuse and Substance Use Disorders

Early intervention services can be provided in a variety of settings (e.g., school clinics, primary care offices, mental health clinics) to people who have problematic use or mild substance use disorders.^17^ These services are usually provided when an individual presents for another medical condition or social service need and is not seeking treatment for a substance use disorder. The goals of early intervention are to reduce the harms associated with substance misuse, to reduce risk behaviors before they lead to injury,^18^ to improve health and social function, and to prevent progression to a disorder and subsequent need for specialty substances use disorder services.^17,18^ Early intervention consists of providing information about substance use risks, normal or safe levels of use, and strategies to quit or cut down on use and use-related risk behaviors, and facilitating patient initiation and engagement in treatment when needed. Early intervention services may be considered the bridge between prevention and treatment services. For individuals with more serious substance misuse, intervention in these settings can serve as a mechanism to engage them into treatment.^17^

### Populations Who Should Receive Early Intervention

Early intervention should be provided to both adolescents and adults who are at risk of or show signs of substance misuse or a mild substance use disorder.^17^ One group typically in need of early intervention is people who binge drink: people who have consumed at least 5 (for men) or 4 (for women) drinks on a single occasion at least once in the past 30 days.^19^ Recent national survey data suggest that over 66 million individuals aged 12 or older can be classified as binge drinkers.^19^ Of particular concern are the 1.4 million binge drinkers aged 12 to 17, who may be at higher risk for future substance use disorders because of their young age.^19^

Other groups who are likely to benefit from early intervention are people who use substances while driving and women who use substances while pregnant. In 2015, an estimated 214,000 women consumed alcohol while pregnant, and an estimated 109,000 pregnant women used illicit drugs.^19^

Available research shows that brief, early interventions, given by a respected care provider, such as a nurse, nurse educator, or physician, in the context of usual medical care (for example, a routine medical exam or care for an injury or illness) can educate and motivate many individuals who are misusing substances to understand and acknowledge their risky behavior and to reduce their substance use.^20,21^

Regardless of the substance, the first step to early intervention is screening to identify behaviors that put the individual at risk for harm or for developing a substance use disorder. Positive screening results should then be followed by brief advice or counseling tailored to the specific problems and interests of the individual and delivered in a non-judgmental manner, emphasizing both the importance of reducing substance use and the individual's ability to accomplish this goal.^17^ Later follow-up monitoring should assess whether the screening and brief intervention were effective in reducing the substance use below risky levels or whether the person needs formal treatment.

### Components of Early Intervention

One structured approach to delivering early intervention to people showing signs of substance misuse and/or early signs of a substance use disorder is through screening and brief intervention (SBI).^22^

Research has shown that several methods of SBI are effective in decreasing “at-risk” substance use and that they work for a variety of populations and in a variety of health care settings.^22,23^ As mentioned earlier, this research has demonstrated positive effects for reducing alcohol use;^24,25^ the research with SBI among those with other substance use disorders has shown mixed results.^26-29^

In addition, research shows that SBI can be cost-effective. For example, a randomized study compared SBI to screening alone for alcohol and drug use disorders among patients covered by Medicaid in eight emergency medicine clinics in the State of Washington. A year later, investigators compared total Medicaid expenditures between the two groups and found that the costs per member, per month for the SBI group were $185 to $192 lower than the costs for the screening-only group. This added up to a savings of more than $2,200 per patient in one year.^30^

FOR MORE ON THIS TOPIC

See Chapter 6 - Health Care Systems and Substance Use Disorders.

#### SBI: Screening

Ideally, substance misuse screening should occur for all individuals who present in health care settings, including primary, urgent, psychiatric, and emergency care. Professional organizations, including the American College of Obstetricians and Gynecologists, the American Medical Association, the American Academy of Family Physicians, and the American Academy of Pediatrics recommend universal and ongoing screening for substance use and mental health issues for adults and adolescents.^31-36^ Such screening practices can help identify the severity of the individual's substance use and whether substance use disorder treatment may be necessary.

Within these contexts, substance misuse can be reliably identified through dialogue, observation, medical tests, and screening instruments.^37^ Several validated screening instruments have been developed to help non-specialty providers identify individuals who may have, or be at risk for, a substance use disorder.

Table 4.1 provides examples of available substance use screening tools, how they are used, and for which age groups. In addition to these tools, single-item screens for presence of drug use (“How many times in the past year have you used an illegal drug or used a prescription medication for nonmedical reasons?”) and for alcohol use (“How many times in the past year have you had X or more drinks in a day?”, where X is 5 for men and 4 for women) have been validated and shown in primary care to accurately identify individuals at risk for or experiencing a substance use disorder.^38-42^

Table 4.1 Evidence-Based Screening Tools for Substance Use

Screening Tool | Substance Type | | Age Group
Screening Tool | Alcohol | Drugs | Adolescents | Adults
Alcohol Screening and Brief Intervention for Adolescents and Youth: A Practitioner's Guide | ✓ | | ✓
Alcohol Use Disorders Identification Test (AUDIT) | ✓ | | | ✓
Alcohol Use Disorders Identification Test-C (AUDIT-C) | ✓ | | | ✓
Brief Screener for Tobacco, Alcohol, and Other Drugs (BSTAD) | ✓ | ✓ | ✓
CRAFFT | ✓ | ✓ | ✓
CRAFFT (Part A) | ✓ | ✓ | ✓
Drug Abuse Screen Test (DAST-10 ) | | ✓ | | ✓
DAST-20: Adolescent version | | ✓ | ✓
Helping Patients Who Drink Too Much: A Clinicians' Guide | ✓ | | ✓ | ✓
NIDA Drug Use Screening Tool | ✓ | ✓ | | ✓
NIDA Drug Use Screening Tool: Quick Screen | ✓ | ✓ | See APA Adapted NM ASSIST tools | ✓
Opioid Risk Tool | | ✓ | | ✓
S2BI | ✓ | ✓ | ✓

Source: National Institute on Drug Abuse, (2015).^43^

#### SBI: Brief Interventions

Brief interventions (or brief advice) range from informal counseling to structured therapies. They often include feedback to the individual about their level of use relative to safe limits, as well as advice to aid the individual in decision-making.^17^

Motivational interviewing (MI) is a client-centered counseling style that addresses a person's ambivalence to change. A counselor uses a conversational approach to help their client discover their interest in changing their substance using behavior. The counselor asks the client to express their desire for change and any ambivalence they might have and then begins to work with the client on a plan to change their behavior and to make a commitment to the change process. The main purpose of MI is to examine and resolve ambivalence, and the counselor is intentionally directive in pursuing this goal.^44^ It is effective in reducing the substance misuse of patients who come to medical settings for other health-related conditions.^45^ In these settings, individuals who receive MI are more likely to adhere to a treatment plan and, subsequently, to have better outcomes.^24,46^

SAMHSA SBIRT Education

SAMHSA offers free SBIRT Continuing Medical Education and Continuing Education courses for providers.

#### Adding Referral to Treatment When Necessary

When an individual's substance use problem meets criteria for a substance use disorder, and/or when brief interventions do not produce change, it may be necessary to motivate the patient to engage in specialized treatment. This is called Screening, Brief Intervention, and Referral to Treatment (SBIRT). In such cases, the care provider makes a referral for a clinical assessment followed by a clinical treatment plan developed with the individual that is tailored to meet the person's needs.^47^ Effective referral processes should incorporate strategies to motivate patients to accept the referral. Although the screening and brief intervention components of SBIRT are the same as SBI, referral to treatment helps the individual access, select, and navigate barriers to substance use disorder treatment.

The literature on the effectiveness of drug-focused brief intervention in primary care and emergency departments is less clear, with some studies finding no improvements among those receiving brief interventions.^48,49^ However, at least one study found significant reductions in subsequent drug use.^50^ Even if brief interventions are not found to be sufficient to address patients' drug use disorders, general health care settings still have an important role to play in addressing drug use disorders, by providing medication-assisted treatment (MAT), providing more robust monitoring and care coordination, and actively promoting engagement in specialty substance use disorder treatment.

Trials evaluating different types of screening and brief interventions for drug use in a range of settings and on a range of patient characteristics are lacking. Recently, efforts have been made to adapt SBIRT for adolescents and for all groups with substance use disorders.^51,52^ The results of preliminary studies are promising,^20,53^ but gaps in knowledge about SBIRT for adolescents still need to be filled.^54^

## Treatment Engagement: Reaching and Reducing Harm Among Those Who Need Treatment

### Populations Who Need Treatment but Are Not Receiving It

FOR MORE ON THIS TOPIC

See Chapter 1 - Introduction and Overview.

Despite the fact that substance use disorders are widespread, only a small percentage of people receive treatment. Results from the 2015 National Survey of Drug Use and Health (NSDUH) reveal that only about 2.2 million people with a substance use disorder, or about 1 in 10 affected individuals, received any type of treatment in the year before the survey was administered.^19^ This “treatment gap” is a large and costly concern for individuals, families, and communities. Of those who needed treatment but did not receive treatment, over 7 million were women and more than 1 million were adolescents aged 12 to 17.^19^ Some racial and ethnic groups experience disparities in entering and receiving substance use disorder treatment services.^55^ For example, approximately 13 million of those who did not receive treatment were non-Hispanic or non-Latino Whites, about 3 million were Hispanics or Latinos, and about 3 million were non-Hispanic Blacks or African Americans.^19^ Among all individuals who met criteria for a substance use disorder, alcohol was by far the most prevalent substance reported, followed by marijuana, misuse of prescription pain relievers, cocaine, and methamphetamines, and about 1 in 10 reported use of multiple substances.^19^ Additionally, over 8 million individuals, or about 40 percent of those with a substance use disorder, also had a mental disorder diagnosed in the year before the survey.^19^ Nonetheless, only 6.8 percent of these individuals received treatment for both conditions, and 52.0 percent received no treatment at all.^19^ Many individuals with substance use disorders also have related physical health problems. Substance use can contribute to medical issues, such as an increased risk of liver, lung, or cardiovascular disease, as well as infectious diseases such as Hepatitis B or C, and HIV/AIDS, and can worsen these health outcomes.^56^

### Reasons for Not Seeking Treatment

There are many reasons people do not seek treatment. The most common reason is that they are unaware that they need treatment; they have never been told they have a substance use disorder or they do not consider themselves to have a problem. This is one reason why screening for substance use disorders in general health care settings is so important. In addition, among those who do perceive that they need substance use disorder treatment, many still do not seek it. For these individuals, the most common reasons given are:^19^

- Not ready to stop using (40.7 percent). A common clinical feature associated with substance use disorders is an individual's tendency to underestimate the severity of their problem and to over-estimate their ability to control it. This is likely due to substance-induced changes in the brain circuits that control impulses, motivation, and decision making.
- Do not have health care coverage/could not afford (30.6 percent).
- Might have a negative effect on job (16.4 percent) or cause neighbors/community to have a negative opinion (8.3 percent).
- Do not know where to go for treatment (12.6 percent) or no program has the type of treatment desired (11.0 percent).
- Do not have transportation, programs are too far away, or hours are inconvenient (11.8 percent).

FOR MORE ON THIS TOPIC

See Chapter 2 - The Neurobiology of Substance Use, Misuse, and Addiction.

The costs of care and lack of insurance coverage are particularly important issues for people with substance use disorders. The 2015 NSDUH found that among individuals who needed and made an effort to get treatment but did not receive specialty substance use treatment, 30.0 percent reported that they did not have insurance coverage and could not afford to pay for treatment.^19^ Thus, a way to reduce health disparities is to increase the number of people who have health insurance. However, even if an individual is insured, the payor may not cover some types or components of substance use disorder treatments, particularly medications.^57,58^ These challenges are magnified further for those who live in rural areas, where substance use disorder treatment services can be distant and thus difficult to reach, as well as expensive because of travel time and cost.^58^

### Strategies to Reduce Harm

Strategies to reduce the harms associated with substance use have been developed as a way to engage people in treatment and to address the needs of those who are not yet ready to participate in treatment. Harm reduction programs provide public health-oriented, evidence-based, and cost-effective services to prevent and reduce substance use-related risks among those actively using substances,^59^ and substantial evidence supports their effectiveness.^60,61^ These programs work with populations who may not be ready to stop substance use – offering individuals strategies to reduce risks while still using substances. Strategies include outreach and education programs, needle/syringe exchange programs, overdose prevention education, and access to naloxone to reverse potentially lethal opioid overdose.^59,62^ These strategies are designed to reduce substance misuse and its negative consequences for the users and those around them, such as transmission of HIV and other infectious diseases.^63^ They also seek to help individuals engage in treatment to reduce, manage, and stop their substance use when appropriate.

#### Outreach and Education

Outreach activities seek to identify those with active substance use disorders who are not in treatment and help them realize that treatment is available, accessible, and necessary. Outreach and engagement methods may include telephone contacts, face-to-face street outreach, community engagement,^64^ or assertive outreach after a referral is made by a clinician or caseworker. These efforts often occur within or in collaboration with programs for intimate partner violence, homelessness, or HIV/AIDS.^65-68^ One study showed that 41 percent of referrals to treatment among substance-using individuals enrolled in a homelessness outreach project successfully resulted in treatment enrollment.^69^ This is notable and promising, but additional research is needed to validate that outreach efforts geared at identifying individuals who need treatment are successful at increasing substance use treatment enrollment and subsequent outcomes.

Educational campaigns are also a common strategy for reducing harms associated with substance use. Such campaigns have historically been targeted toward substance-using individuals, giving them information and guidance on risks associated with sharing medications or needles, how to access low or no-cost treatment services, and how to prevent a drug overdose death.^59,61^ Other education campaigns target the overall public to improve general understanding about addiction, community health and safety risks, and how to access available treatment services.^70-72^ Two examples are SAMHSA's National Recovery Month, which seeks to increase awareness and understanding of mental and substance use issues, and the Anyone.Anytime. campaign in New Hampshire, which was implemented statewide to educate the public and professionals about addiction, emergency overdose medication, and accessibility to support services for those with opioid use disorders. The National Highway Traffic Safety Administration's (NHTSA's) annual Drive Sober or Get Pulled Over campaign is another example, aimed at reducing drunk driving and preventing alcohol-impaired fatalities.

#### Needle/Syringe Exchange Programs

Drugs such as heroin and other opioids, cocaine, and methamphetamine are commonly used by injection, and this route of administration has been a major source of infectious disease transmission including HIV, Hepatitis B, Hepatitis C, and other blood-borne diseases. Data from the CDC reveal that even though HIV among people who inject drugs is declining, it is still a significant problem: 7 percent (3,096) of the 47,352 newly diagnosed cases of HIV infection in the United States in 2013 were attributable to injection drug use, and another 3 percent (1,270) involved male-to-male sexual contact combined with injection drug use.^73,74^ Nearly 20,000 people died from Hepatitis C in 2014, and 3.5 million are living with Hepatitis C. New cases of Hepatitis C infection increased 250 percent between 2010 and 2014, and occur primarily among young White people who inject drugs.^75^

Because of these data, providing sterile needles and syringes to people who inject drugs has become an important strategy for reducing disease transmission. The goal of needle/syringe exchange programs is to minimize infection transmission risks by giving individuals who inject drugs sterile equipment and other support services at little or no cost.^76^ Additional services from these programs often include HIV/AIDS counseling and testing; strategies and education for preventing sexually transmitted infections, including condom use and use of medications before or after exposure to HIV to reduce the risk of becoming infected (pre-exposure prophylaxis [PrEP] or post-exposure prophylaxis [PEP]); and other health care services. Needle/syringe exchange programs also attempt to encourage individuals to engage in substance use disorder treatment.^77^

Evaluation studies have clearly shown that needle/syringe exchange programs are effective in reducing HIV transmission and do not increase rates of community drug use.^78^ However, most of the research has not examined the impact of these programs on Hepatitis C transmission, therefore currently available data are insufficient to address this question.^79^

#### Naloxone

Opioid overdose incidents and deaths, either from prescription pain relievers or heroin, are a serious threat to public health in the United States. Overdose deaths from opioid pain relievers and heroin have risen dramatically in the past 14 years,^80^ from 5,990 in 1999 to 29,467 in 2014, and most were preventable. Rates of opioid overdose deaths are particularly high among individuals with an opioid use disorder who have recently stopped their use as a result of detoxification or incarceration. As a result, their tolerance for the drug is reduced, making them more vulnerable to an overdose. Those who mix opioids with alcohol, benzodiazepines, or other drugs also have a high risk of overdose.^59^

Opioid overdose does not occur immediately after a person has taken the drug. Rather, the effects develop gradually as the drug depresses a person's breathing and heart rate. This eventually leads to coma and death if the overdose is not treated. This gradual progress means that there is typically a 1- to 3-hour window of opportunity after a user has taken the drug in which bystanders can take action to prevent the user's death.^59^

Naloxone is an opioid antagonist medication approved by the FDA to reverse opioid overdose in injectable and nasal spray forms. It works by displacing opioids from receptors in the brain, thereby blocking their effects on breathing and heart rate.

The rising number of deaths from opioid overdose has led to increasing public health efforts to make naloxone available to at-risk individuals and their families, as well as to emergency medical technicians, police officers, and other first responders, or through community-based opioid overdose prevention programs. Although regulations vary by state, some states have passed laws expanding access to naloxone without a patient-specific prescription in some localities.^81,82^ Additionally, some schools across the country are stocking naloxone for use by trained nurses.

Interventions that distribute take-home doses of naloxone along with education and training for those actively using opioids and their peers and family members, have the potential to help decrease overdose-related deaths.^83,84^ Current evidence from nonrandomized studies also suggests that family, friends, and other community members who are properly trained can and will administer naloxone appropriately during an overdose incident.^85^ And, despite concern that access to naloxone might increase the prevalence or frequency of opioid use, research demonstrates that neither of these problems has occurred.^86^

FDA Approval of Naloxone Nasal Spray

Naloxone, a safe medication that can quickly restore normal breathing to a person in danger of dying from an opioid overdose, is already carried by emergency medical personnel and other first responders. But by the time an overdosing person is reached and treated, it is often too late to save them. To solve this problem, several experimental Overdose Education and Naloxone Distribution (OEND) programs have given naloxone directly to opioid users, their friends or loved ones, and other potential bystanders, along with brief training on how to use this medication. These programs have been shown to be an effective, as well as cost-effective, way of saving lives.

Until recently, only injectable forms of naloxone were approved by the FDA. However, in November 2015, the FDA approved a user-friendly intranasal formulation of naloxone that matches the injectable version in terms of how much of the medication gets into the body and how rapidly. According to the CDC, more than 74 Americans die each day from an overdose involving prescription pain relievers or heroin. To reverse these trends, it is important to do everything possible to ensure that emergency personnel, as well as at-risk opioid users and their loved ones, have access to lifesaving medications like naloxone.

### Acute Stabilization and Withdrawal Management

Withdrawal management, often called “detoxification,” includes interventions aimed at managing the physical and emotional symptoms that occur after a person stops using a substance. Withdrawal symptoms vary in intensity and duration based on the substance(s) used, the duration and amount of use, and the overall health of the individual. Some substances, such as alcohol, opioids, sedatives, and tranquilizers, produce significant physical withdrawal effects, while other substances, such as marijuana, stimulants, and caffeine, produce primarily emotional and cognitive withdrawal symptoms. Most periods of withdrawal are relatively short (3 to 5 days) and are managed with medications combined with vitamins, exercise, and sleep. One important exception is withdrawal from alcohol and sedatives/tranquilizers, especially if the latter are combined with heavy alcohol use. Rapid or unmanaged withdrawal from these substances can be protracted and can produce seizures and other health complications.^56^

Withdrawal management is highly effective in preventing immediate and serious medical consequences associated with discontinuing substance use,^56^ but by itself it is not an effective treatment for any substance use disorder. It is best considered stabilization: The patient is assisted through a period of acute detoxification and withdrawal to being medically stable and substance-free. Stabilization includes preparing the individual for treatment and involving the individual's family and other significant people in the person's life, as appropriate, to support the person's treatment process. Stabilization is considered a first step toward recovery, much like acute management of a diabetic coma or a hypertensive stroke is simply the first step toward managing the underlying illness of diabetes or high blood pressure. Similarly, acute stabilization and withdrawal management are most effective when following evidence-based standards of care.^87^

Unfortunately, many individuals who receive withdrawal management do not become engaged in treatment. Studies have found that half to three quarters of individuals with substance use disorders who receive withdrawal management services do not enter treatment.^88^ One common result of not engaging in continuing care is rapid readmission to a detoxification center, an emergency department, or a hospital. For example, 27 percent of people who received detoxification services not followed by continuing care were readmitted within 1 year to public detoxification services in Delaware, Oklahoma, and Washington.^89^ Beginning substance use disorder treatment within 14 days of discharge from withdrawal management, however, has been shown to reduce readmission rates.^90^

One of the most serious consequences when individuals do not begin continuing care after withdrawal management is overdose. Because withdrawal management reduces much of an individual's acquired tolerance, those who attempt to re-use their former substance in the same amount or frequency can experience physical problems. Individuals with opioid use disorders may be left particularly vulnerable to overdose and even death. It is critically important for health care providers to be prepared to properly assess the nature and severity of their patients' clinical problems following withdrawal so that they can facilitate engagement into the appropriate intensity of treatment.^56^

## Principles of Effective Treatment and Treatment Planning

### Principles and Goals of Treatment

Treatment can occur in a variety of settings but most treatment for substance use disorders has traditionally been provided in specialty substance use disorder treatment programs. For this reason, the majority of research has been performed within these specialty settings.^91^ The following sections describe what is known from this research about the processes, stages of, and outcomes from traditional substance use disorder treatment programs.

The National Institute on Drug Abuse (NIDA) has detailed the evidence-based principles of effective treatment for adults and adolescents with substance use disorders that apply regardless of the particular setting of care or type of substance use disorder treatment program (Table 4.2).^85,92^

Table 4.2 Principles of Effective Treatment for Substance Use Disorders

Principles of Effective Treatment for Adults | Principles of Effective Treatment for Adolescents
1. Addiction is a complex but treatable disease that affects brain function and behavior.; 2. No single treatment is appropriate for everyone.; 3. Treatment needs to be readily available.; 4. Effective treatment attends to multiple needs of the individual, not just his or her drug abuse.; 5. Remaining in treatment for an adequate period of time is critical.; 6. Behavioral therapies—including individual, family, or group counseling-- are the most commonly used forms of drug abuse treatment.; 7. Medications are an important element of treatment for many patients, especially when combined with counseling and other behavioral therapies.; 8. An individual's treatment and services plan must be assessed continually and modified as necessary to ensure that it meets his or her changing needs.; 9. Many drug-addicted individuals also have other mental disorders.; 10. Medically assisted detoxification is only the first stage of addiction treatment and by itself does little to change long-term drug abuse.; 11. Treatment does not need to be voluntary to be effective.; 12. Drug use during treatment must be monitored continuously, as lapses during treatment do occur.; 13. Treatment programs should test patients for the presence of HIV/AIDS, Hepatitis B and C, tuberculosis, and other infectious diseases, provide risk-reduction counseling, and link patients to treatment if necessary. | 1. Adolescent substance use needs to be identified and addressed as soon as possible.; 2. Adolescents can benefit from a drug abuse intervention even if they are not addicted to a drug.; 3. Routine annual medical visits are an opportunity to ask adolescents about drug use.; 4. Legal interventions and sanctions or family pressure may play an important role in getting adolescents to enter, stay in, and complete treatment.; 5. Substance use disorder treatment should be tailored to the unique needs of the adolescent.; 6. Treatment should address the needs of the whole person, rather than just focusing on his or her drug use.; 7. Behavioral therapies are effective in addressing adolescent drug use.; 8. Families and the community are important aspects of treatment.; 9. Effectively treating substance use disorders in adolescents requires also identifying and treating any other mental health conditions they may have.; 10. Sensitive issues such as violence and child abuse or risk of suicide should be identified and addressed.; 11. It is important to monitor drug use during treatment.; 12. Staying in treatment for an adequate period of time and continuity of care afterward are important.; 13. Testing adolescents for sexually transmitted diseases like HIV, as well as Hepatitis B and C, is an important part of drug treatment.

Source: National Institute on Drug Abuse, (2012)^85^ and (2014).^92^

The goals of substance use disorder treatment are similar to those of treatments for other serious, often chronic, illnesses: reduce the major symptoms of the illness, improve health and social function, and teach and motivate patients to monitor their condition and manage threats of relapse. Substance use disorder treatment can be provided in inpatient or outpatient settings, depending on the needs of the patient, and typically incorporates a combination of behavioral therapies, medications, and RSS. However, unlike treatments for most other medical illnesses, substance use disorder treatment has traditionally been provided in programs (both residential and outpatient) outside of the mainstream health care system. The intensity of the treatment regimens offered can vary substantially across program types. The American Society of Addiction Medicine (ASAM) has categorized these programs into “levels” of care to guide referral based on an individual patient's needs.^93-95^

Despite differences in care delivery and differences in reimbursement, substance use disorder treatments have approximately the same rates of positive outcomes as treatment for other chronic illnesses. Relapse rates for substance use disorders (40 to 60 percent) are comparable to those for chronic diseases, such as diabetes (20 to 50 percent), hypertension (50 to 70 percent), and asthma (50 to 70 percent).^12^

KEY CONCEPT

Treatment varies depending on substance(s) used, severity of substance use disorder, comorbidities, and the individual's preferences.

Treatment typically includes medications and counseling as well as other social supports such as linkage to community recovery groups depending on an individual patient's needs and level of existing family and social support.

The general process of treatment planning and delivery for individuals with severe substance use disorders is described below, along with an explanation of the evidence-based therapies, medications, and RSS shown to be effective in treatment.

### Treatment Planning

#### Assessment and Diagnosis

Among the first steps involved in substance use disorder treatment are assessment and diagnosis. The diagnosis of substance use disorders is based primarily on the results of a clinical interview. Several assessment instruments are available to help structure and elicit the information required to diagnose substance use disorders. The diagnosis of a substance use disorder is made by a trained professional based on 11 symptoms defined in the Fifth Edition of the Diagnostic and Statistical Manual of Mental Disorders (DSM-5). These symptoms, which are generally related to loss of control over substance use,^96^ are presented in Table 1.5^2^ in Chapter 1. The number of diagnostic symptoms present defines the severity of the disorder, ranging from mild to severe (i.e., fewer than 2 symptoms = no disorder; 2 to 3 symptoms = mild disorder; 4 to 5 symptoms = moderate disorder; 6 or more symptoms = severe disorder).^97^

FOR MORE ON THIS TOPIC

See Chapter 1 - Introduction and Overview.

Conducting a clinical assessment is essential to understanding the nature and severity of the patient's health and social problems that may have led to or resulted from the substance use. This assessment is important in determining the intensity of care that will be recommended and the composition of the treatment plan.^91^ Several validated assessment tools can provide information about an individual's substance use disorder. Table 4.3 gives a brief overview of some of the tools that are available.

Table 4.3 Detailed Information on Substance Use Disorder Assessment Tools

Addiction Severity Index (ASI)^98^ | Substance Abuse Module (SAM)^99^ | Global Appraisal of Individual Needs (GAIN)^299^ | Psychiatric Research Interview for Substance and Mental Disorders (PRISM)^100^
- Semi-structured interview.; - Addresses seven potential problem areas in substance using individuals: medical status, employment and support, drug use, alcohol use, legal status, family/social status, and psychiatric status.; - Provides an overview of problems related to substance, rather than focusing on any single area.; - Used extensively for treatment planning and outcome evaluation.; - A shorter, self-report version of the ASI called the ASI-Lite is also available. | - Expanded and more detailed version of the substance use section of the Composite International Diagnostic Interview (CIDI).; - Designed to assess mental disorders as defined by the Diagnositic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV).; - Contains four diagnostic sections on tobacco, alcohol, drugs, and caffeine.; - Includes questions about when symptoms began and how recent they are, withdrawal symptoms, and the physical, social and psychological consequences of each substance assessed.; - Assesses the respondent's impairment and treatment seeking.; - Can assess substance use disorders quickly and accurately in the clinical setting. | - Series of measures (screener, standardized biopsychosocial intake assessment battery, follow-up assessment battery) which integrate research and clinical assessment.; - Contains 99 scales and subscales, that are designed to measure the recency, breadth, and frequency of problems and service utilization related to substance use (including diagnosis and course, treatment motivation, and relapse potential), physical health, risk/protective involvement, mental health, environment and vocational situation.; - Can assess change over time. | - Semi-structured, clinician-administered interview.; - Measures the major DSM-IV diagnoses of alcohol, drug, and psychiatric disorders.; - Provides clear guidelines for differentiating between the effects of intoxication and withdrawal, substance-induced disorders, and primary disorders.

#### Individualized Treatment Planning

After a formal assessment, the information is discussed with the patient to jointly develop a personalized treatment plan designed to address the patient's needs.^91,101^ The treatment plan and goals should be person-centered and include strength-based approaches, or ones that draw upon an individual's strengths, resources, potential, and ability to recover, to keep the patient engaged in care. Individualized treatment plans should consider age, gender identity, race and ethnicity, language, health literacy, religion/spirituality, sexual orientation, culture, trauma history, and co-occurring physical and mental health problems. Such considerations are critical for understanding the individual and for tailoring the treatment to his or her specific needs. This increases the likelihood of successful treatment engagement and retention, and research shows that those who participate more fully in treatment typically have better outcomes.^102^ Throughout treatment, individuals should be periodically reassessed to determine response to treatment and to make any needed adjustments to the treatment plan.

#### Maintaining Treatment Engagement and Retention

Treatment plans should be personalized and include engagement and retention strategies to promote participation, motivation, and adherence to the plan.^47^ Research has found that individuals who received proactive engagement services such as direct outreach and a specific follow-up plan are more likely to remain engaged in services throughout the treatment process.^47,103,104^

Treatment providers can improve engagement and retention in programs by building a strong therapeutic alliance with the patient, effectively using evidence-based motivational strategies, acknowledging the patient's individual barriers, making reminder phone calls, and creating a positive environment.^105^ Further, providers who can recommend and/or provide a broad range of RSS, such as child care, housing, and transportation, can improve retention in treatment.^106^

Engaging, effective treatment also involves culturally competent care. For example, treatment programs that provide gender-specific and gender-responsive care are more likely to enhance women's treatment outcomes.^107^ Tailoring treatment to involve family and community is particularly effective for certain groups. For example, American Indians or Alaska Natives may require specific elements in their treatment plan that respond to their unique cultural experiences and to intergenerational and historical trauma and trauma from violent encounters.^108^ Language and literacy (including health literacy) may also affect how a person responds to the treatment environment.^109-112^ Race and ethnicity, sexual orientation, gender identity, and economic status can play significant roles in treatment initiation, engagement, and completion.^107,113,114^

Substance use disorder treatment programs also have an obligation to prepare for disasters within their communities that can affect the availability of services. A disaster can disrupt a program's ability to provide treatment services or an individual's ability to maintain treatment. Individuals in recovery, for example, may relapse due to sudden discontinuation of services or stress when having to cope with effects of a disaster. Individuals receiving MAT could be at risk of serious withdrawal symptoms if medications are stopped abruptly. Others may face challenges without their treatment program's support.^115^ Therefore, planning for disasters and other large scale emergencies is critical to prevent or reduce the impact of interruptions in treatment services.

#### Treatment Setting and the Continuum of Care

As indicated above, the treatment of addiction is delivered in predominantly freestanding programs that differ in their setting (hospital, residential, or outpatient); in the frequency of care delivery (daily sessions to monthly visits); in the range of treatment components offered; and in the planned duration of care. In general, as patients progress in treatment and begin to meet the goals of their individualized treatment plan, they transfer from clinical management in residential or intensive outpatient programs to less clinically intensive outpatient programs that promote patient self-management.

A typical progression for someone who has a severe substance use disorder might start with 3 to 7 days in a medically managed withdrawal program, followed by a 1- to 3-month period of intensive rehabilitative care in a residential treatment program, followed by continuing care, first in an intensive outpatient program (2 to 5 days per week for a few months) and later in a traditional outpatient program that meets 1 to 2 times per month. For many patients whose current living situations are not conducive to recovery, outpatient services should be provided in conjunction with recovery-supportive housing.

FOR MORE ON THIS TOPIC

See Chapter 5 - Recovery: The Many Paths to Wellness.

In general, patients with serious substance use disorders are recommended to stay engaged for at least 1 year in the treatment process, which may involve participation in three to four different programs or services at reduced levels of intensity, all of which are ideally designed to help the patient prepare for continued self-management after treatment ends.^56,116^ This expected trajectory of care explains why efforts to maintain patient motivation and engagement are important. Brief summaries of the major levels of the treatment continuum are discussed below.

Medically monitored and managed inpatient care is an intensive service delivered in an acute, inpatient hospital setting.^18^ These programs are typically necessary for individuals who require withdrawal management, primary medical and nursing care, and for those with co-occurring mental and physical health conditions.^18^ Treatment is usually provided by an interdisciplinary team of health care professionals, available 24 hours a day, who can address serious mental and physical health needs.^18,91^

FOR MORE ON THIS TOPIC

See the section on “Acute Stabilization and Withdrawal Management” earlier in this chapter.

Residential services offer organized services, also in a 24-hour setting but outside of a hospital. These programs typically provide support, structure, and an array of evidence-based clinical services.^18^ Such programs are appropriate for physically and emotionally stabilized individuals who may not have a living situation that supports recovery, may have a history of relapse, or have co-occurring physical and/or mental illnesses.

Partial hospitalization and intensive outpatient services range from counseling and education to clinically intensive programming.^18^ Partial hospitalization programs are used as a step-down treatment option after completing residential treatment and are usually available 6 to 8 hours a day during the work week.^18^ These services are considered to be approximately as intensive but less restrictive than residential programs^91^ and are appropriate for patients living in an environment that supports recovery but who need structure to avoid relapse.

Outpatient services provide both group and individual behavioral interventions and medications when appropriate.^91^ These components of care can be offered during the day, before or after work or school, or in the evenings and weekends. Typically, outpatient programs are appropriate as the initial level of care for individuals with a mild to moderate substance use disorder or as continuing care after completing more intensive treatment.^18^ Outpatient programs are also suitable for individuals with co-occurring mental health conditions.

## Evidence-based Treatment: Components of Care

Regardless of the substance for which the individual seeks treatment or the setting or level of care, all substance use disorder treatment programs are expected to offer an individualized set of evidence-based clinical components. These components are clinical practices that research has shown to be effective in reducing substance use and improving health and functioning. These include behavioral therapies, medications, and RSS. Treatment programs that offer more of these evidence-based components have the greatest likelihood of producing better outcomes.

Evidence-Based Practices

Research continues to identify new effective components of care. SAMHSA manages the National Registry of Evidence-based Programs and Practices (NREPP) that was developed to inform the public and to guide individual choices about treatment.

### Medications and Medication-Assisted Treatment

Five medications, approved by the FDA, have been developed to treat alcohol and opioid use disorders. Currently, no approved medications are available to treat marijuana, amphetamine, or cocaine use disorders.^117^ Table 4.4 lists these medications and they are discussed individually in the text that follows.

Table 4.4 Pharmacotherapies Used to Treat Alcohol and Opioid Use Disorders

Medication | Use | Dosage Form | DEA Schedule^*^ | Application
Buprenorphine-Naloxone | Opioid use disorder | Sublingual film^**^:^118^ 2mg/0.5mg, 4mg/1mg, 8mg/2mg, and 12mg/3mg Sublingual tablet: 1.4mg/0.36mg, 2mg/0.5mg, 2.9/0.71mg, 5.7mg/1.4mg, 8mg/2mg, 8.6mg/2.1mg, 11.4mg/2.9mg Buccal film: 2.1mg/0.3mg, 4.2mg/0.7mg, 6.3mg/1mg | CIII | Used for detoxification or maintenance of abstinence for individuals aged 16 or older. Physicians who wish to prescribe buprenorphine, must obtain a waiver from SAMHSA and be issued an additional registration number by the U.S. Drug Enforcement Administration (DEA).
Buprenorphine Hydrochloride | Opioid use disorder | Sublingual tablet: 2mg, 4mg, 8mg, and 12mg | CIII | This formulation is indicated for treatment of opioid dependence and is preferred for induction. However, it is considered the preferred formulation for pregnant patients, patients with hepatic impairment, and patients with sensitivity to naloxone. It is also used for initiating treatment in patients transferring from methadone, in preference to products containing naloxone, because of the risk of precipitating withdrawal in these patients.
| | Probuphine® implants: 80mgx4 implants for a total of 320mg | | For those already stable on low to moderate dose buprenorphine. The administration of the implant dosage form requires specific training and must be surgically inserted and removed.
Methadone | Opioid use disorder | Tablet: 5mg, 10mg Tablet for suspension: 40mg Oral concentrate: 10mg/mL Oral solution: 5mg/5mL,10mg/5mL Injection: 10mg/mL | CII | Methadone used for the treatment of opioid addiction in detoxification or maintenance programs shall be dispensed only by Opioid Treatment Programs (OTPs) certified by SAMHSA and approved by the designated state authority. Under federal regulations it can be used in persons under age 18 at the discretion of an OTP physician.^119^
Naltrexone | Opioid use disorder; alcohol use disorder | Tablets: 25mg, 50mg, and 100mg Extended-release injectable suspension: 380mg/vial | Not Scheduled under the Controlled Substances Act | Provided by prescription; naltrexone blocks opioid receptors, reduces cravings, and diminishes the rewarding effects of alcohol and opioids. Extended-release injectable naltrexone is recommended to prevent relapse to opioids or alcohol. The prescriber need not be a physician, but must be licensed and authorized to prescribe by the state.
Acamprosate | Alcohol use disorder | Delayed-release tablet: 333mg | Not Scheduled under the Controlled Substances Act | Provided by prescription; acamprosate is used in the maintenance of alcohol abstinence. The prescriber need not be a physician, but must be licensed and authorized to prescribe by the state.
Disulfiram | Alcohol use disorder | Tablet: 250mg, 500mg | Not Scheduled under the Controlled Substances Act | When taken in combination with alcohol, disulfiram causes severe physical reactions, including nausea, flushing, and heart palpitations. The knowledge that such a reaction is likely if alcohol is consumed acts as a deterrent to drinking.

Notes:

* For more information about the DEA Schedule and classification of specific drugs, see Appendix D - Important Facts about Alcohol and Drugs.

** This dosage form may be used via sublingual or buccal routes of administration; sublingual means placed under the tongue, buccal means applied to the buccal area (in the cheek).

Source: Adapted from Lee et al., (2015).^120^

Like all other FDA-approved medications, those listed in Table 4.4 demonstrate “well-supported” experimental evidence of safety and effectiveness^120^ for improving outcomes for individuals with alcohol and opioid use disorders.^117^ At the same time, all of these medications have side effects; two (methadone and buprenorphine) have the potential to be misused, and methadone (and to a lesser extent buprenorphine) has the potential for overdose. For these reasons, only appropriately trained health care professionals should decide whether medication is needed as part of treatment, how the medication is provided in the context of other clinical services, and under what conditions the medication should be withdrawn or terminated.

The combination of behavioral interventions and medications to treat substance use disorders is commonly referred to as MAT.^121^ MAT is a highly effective treatment option for individuals with alcohol and opioid use disorders. Studies have repeatedly demonstrated the efficacy of MAT at reducing illicit drug use and overdose deaths,^122,123^ improving retention in treatment,^124^ and reducing HIV transmission.^122^

Some medications used to treat opioid use disorders can be used to manage withdrawal and as maintenance treatment to reduce craving, lessen withdrawal symptoms, and maintain recovery.^56^ These medications are used to help a patient function comfortably without illicit opioids or alcohol while balance is gradually restored to the brain circuits that have been altered by prolonged substance use.

FOR MORE ON THIS TOPIC

See Chapter 2 - The Neurobiology of Substance Use, Misuse, and Addiction.

Prescribed in this fashion, medications for substance use disorders are in some ways like insulin for patients with diabetes. Insulin reduces symptoms by normalizing glucose metabolism, but it is part of a broader disease control strategy that also employs diet change, education on healthy living, and self-monitoring. Whether treating diabetes or a substance use disorder, medications are best employed as part of a broader treatment plan involving behavioral health therapies and RSS, as well as regular monitoring.

State agencies that oversee substance use disorder treatment programs use a variety of strategies to promote implementation of MAT, including education and training, financial incentives (e.g., linking funding to the provision of MAT), policy mandates, and support for infrastructure development.^5^ Nevertheless, multiple factors create barriers to widespread use of MAT. These include provider, public, and client attitudes and beliefs about MAT; lack of an appropriate infrastructure for providing medications; need for staff training and development; and legislation, policies, and regulations that limit MAT implementation.^5^

#### Medication-Assisted Treatment for Opioid Use Disorders

MAT for patients with a chronic opioid use disorder must be delivered for an adequate duration in order to be effective. Patients who receive MAT for fewer than 90 days have not shown improved outcomes.^125^ One study suggested that individuals who receive MAT for fewer than 3 years are more likely to relapse than those who are in treatment for 3 or more years.^126^ Three medications are commonly used to treat opioid use disorders: methadone, buprenorphine, and naltrexone.

Methadone is a synthetic opioid agonist that has been used to treat the symptoms of withdrawal from heroin and other opioids.^127^ More than 40 years of research support the use of methadone as an effective treatment for opioid use disorder.^121,128,129^ It is also used in the treatment of patients with chronic, severe pain^130^ as a therapeutic alternative to morphine sulfate and other opioid analgesics.^131^ Any licensed physician can prescribe methadone for the treatment of pain, but methadone may only be dispensed for treatment of an opioid use disorder within licensed methadone treatment programs.

KEY TERMS

Agonist. A chemical substance that binds to and activates certain receptors on cells, causing a biological response. Fentanyl and methadone are examples of opioid receptor agonists.

Long-term methadone maintenance treatment for opioid use disorders has been shown to be more effective than short-term withdrawal management,^132^ and it has demonstrated improved outcomes for individuals (including pregnant women and their infants) with opioid use disorders.^133^ Studies have also indicated that methadone reduces deaths, HIV risk behaviors, and criminal behavior associated with opioid drug seeking.^134,135^

The use of methadone to treat opioid use disorders has much in common with treatments for other substance use disorders and other chronic illnesses. However, it has one significant structural and cultural difference. Under regulations dating back to the early 1970s, the federal government created special methadone programs for adults with opioid use disorders. Originally referred to as “methadone treatment programs,” these treatment facilities were created to provide special management of the medical and legal issues associated with the use of this potent, long-acting opioid.

The use of opioid agonist medications to treat opioid use disorders has always had its critics. Many people, including some policymakers, authorities in the criminal justice system, and treatment providers, have viewed maintenance treatments as “substituting one substance for another”^85^ and have adhered instead to an abstinence-only philosophy that avoids the use of medications, especially those that activate opioid receptors. Such views are not scientifically supported; the research clearly demonstrates that MAT leads to better treatment outcomes compared to behavioral treatments alone. Moreover, withholding medications greatly increases the risk of relapse to illicit opioid use and overdose death. Decades of research have shown that the benefits of MAT greatly outweigh the risks associated with diversion.

KEY TERMS

Drug diversion. A medical and legal concept involving the transfer of any legally prescribed controlled substance from the person for whom it was prescribed to another person for any illicit use.

Today, methadone treatment programs, now called Opioid Treatment Programs (OTPs), must be certified by SAMHSA and registered by the U.S. Drug Enforcement Administration (DEA). OTPs are predominantly outpatient programs (approximately 95 percent) that provide pharmacotherapy in combination with behavioral therapies and other RSS.^136^ OTPs incorporate principles of harm reduction and benefit both program participants and the community^137^ by reducing opioid use, mortality, crime associated with opioid use disorders, and infectious disease transmission. Buprenorphine and naltrexone may also be provided in OTPs.^61^

Individuals receiving medication for opioid use disorders in an OTP must initially take their doses daily under observation.^138,139^ After a period of orientation, patients are typically started at a dose of 20 to 30 mg and gradually increased to 80 mg or more per day, until craving and opioid misuse are significantly reduced. During this period, all dosing occurs at the OTP, but following stabilization and initially positive results, the stabilized patient may be given a “take-home” supply of his or her dose to self-administer per the federal opioid treatment standard regulations 42 CFR 8.12(i).

Buprenorphine is available as a sublingual tablet and a sublingual or buccal film. In addition, in May 2016, an implantable formulation of buprenorphine was approved by the FDA. For individuals who are already on a stable low to moderate dose of buprenorphine, the implant delivers a constant low dose of buprenorphine for 6 months. Buprenorphine is associated with improved outcomes compared to placebo for individuals (including pregnant women and their infants) with opioid use disorders,^140^ and it is effective in reducing illegal opioid use.^129^

Buprenorphine is a partial opioid agonist, meaning that it binds to and activates opioid receptors but with less intensity than full agonists. As a result, there is an upper limit to how much euphoria, pain relief, or respiratory depression buprenorphine can produce.^56,141^ However, buprenorphine still may result in overdose if used with tranquilizers and/or alcohol, and some diversion has been reported, although studies suggest most diverted buprenorphine is used therapeutically (e.g., to control cravings), not to get high.^142-144^

Clinical experience and research protocols indicate that buprenorphine initiation and stabilization during the induction period is an important part of successful treatment for individuals with opioid use disorder.^145^ Buprenorphine can be prescribed alone or as a combination medication that includes naloxone, an opioid antagonist medication.^145^ If this combined medication is taken as prescribed, the naloxone has no appreciable effects. However, if the combined medication is injected, the naloxone component can precipitate an opioid withdrawal syndrome, and in this way serves as a deterrent to misuse by injection.^145^

Buprenorphine may be prescribed by physicians who have met the statutory requirements for a waiver in accordance with the Controlled Substances Act (21 U.S.C. 823(g)(2)(D)(iii)).^146^ However, physicians using the waiver are limited in the number of patients they can treat with this medication. This patient limit does not apply to OTPs that dispense buprenorphine on site because the OTP operating in this capacity is doing so under 21 U.S.C. 823(g)(1) and 42 CFR Part 8, and not under 21 U.S.C. 823(g)(2)(B).

When they first receive their waiver, physicians can provide buprenorphine treatment for only up to 30 individuals. After the first year they can request to treat up to 100.^147^ However, lack of physician availability to prescribe buprenorphine has been a significant limitation on access to this effective medication. Although approximately 435,000 primary care physicians practice medicine in the United States,^148^ only slightly more than 30,000 have a buprenorphine waiver,^149^ and only about half of those are actually treating opioid use disorders.^150^ To address this limitation and narrow the treatment gap, a final rule was published on July 8, 2016, expanding access to MAT by allowing eligible practitioners to request approval to treat up to 275 patients.^147^

Additionally, on July 22, 2016, the Comprehensive Addiction and Recovery Act (CARA) was signed into law. CARA temporarily expands eligibility to prescribe buprenorphine-based drugs for MAT for substance use disorders to qualifying nurse practitioners and physician assistants through October 1, 2021.

FOR MORE ON THIS TOPIC

See the section on “Comprehensive Addiction and Recovery Act (CARA)” in Chapter 6 - Health Care Systems and Substance Use Disorders.

Naltrexone is an opioid antagonist that binds to opioid receptors and blocks their activation; it produces no opioid-like effects and is not abusable. It prevents other opioids from binding to opioid receptors so that they have little to no effect. It also interrupts the effects of any opioids in a person's system, precipitating an opioid withdrawal syndrome in opioid-dependent patients, so it can be administered only after a complete detoxification from opioids. There is also no withdrawal from naltrexone when the patient stops taking it. Naltrexone may be appropriate for people who have been successfully treated with buprenorphine or methadone who wish to discontinue use but still be protected from relapse; people who prefer not to take an opioid agonist; people who have completed detoxifications and/or rehabilitation or are being released from incarceration and expect to return to an environment where drugs may be used and wish to avoid relapse; and adolescents or young adults with opioid dependence.^151^

Because naltrexone is not a controlled substance, it can be prescribed or administered by any physician, nurse practitioner, or physician assistant with prescribing authority. Naltrexone comes in two formulations: oral and extended-release injectable. Oral naltrexone can be effective for those individuals who are highly motivated and/or supported with observed daily dosing. Extended-release injectable naltrexone, which is administered on a monthly basis, addresses the poor compliance associated with oral naltrexone since it provides extended protection from relapse and reduces cravings for 30 days.^152,153^

#### Medication-Assisted Treatment for Alcohol Use Disorders

A number of factors should be weighed in determining the need for medication when treating an individual for an alcohol use disorder, such as the patient's motivation for treatment, potential for relapse, and severity of co-existing conditions.^120^ Three FDA-approved medications are currently available to treat alcohol use disorder: disulfiram, naltrexone, and acamprosate.^117^ None of these medications carries a risk of misuse or addiction, and thus none is a DEA-scheduled substance. Each has a distinct effectiveness and side effect profile. Prescribing health care professionals should be familiar with these side effects and take them into consideration before prescribing.^154^ Providers can obtain additional information from materials produced by the National Institute on Alcohol Abuse and Alcoholism (NIAAA) and SAMHSA.^155,156^

Research studies on the efficacy of medications to treat alcohol use disorders have demonstrated that most patients show benefit, although individual response can be difficult to predict.^154,157^ MAT interventions for alcohol use disorders can be provided in both non-specialty and specialty care settings and are most beneficial when combined with behavioral interventions and brief support.^154^

Disulfiram is a medication that inhibits normal breakdown of acetaldehyde which is produced by the metabolism of alcohol, thus rapidly increasing acetaldehyde in the blood which produces an aversive response. Thus, once disulfiram is taken by mouth, any alcohol consumed results in rapid buildup of acetaldehyde and a negative reaction or sickness results. The intensity of this reaction is dependent on the dose of disulfiram and the amount of alcohol consumed.^158^ Effects from a disulfiram-alcohol reaction include warmth and flushing of the skin, increased heart rate, palpitations, a drop in blood pressure, nausea and/or vomiting, sweating, dizziness, and headache.^159^ In this way, disulfiram essentially punishes alcohol consumption and indirectly rewards abstinence.^117^

Disulfiram was the first medication approved by the FDA to treat alcohol use disorder and its efficacy has been widely studied.^160^ Most studies have demonstrated that disulfiram, when given under supervision, is more effective than placebo in treating alcohol use disorders.^154^ A major limitation of disulfiram is adherence, which is typically poor, thereby reducing the medication's effectiveness. Disulfiram is most effective when its use is supervised or observed, which has been found to increase compliance.^154,159^ Negotiating with the patient to have a spouse or significant other provide supervision offers both the incentive to take the medication and the documentation that the medication is being taken.^161^ The best candidates for disulfiram are patients with motivation for treatment and a desire to be abstinent. Thus, an individual who wants to reduce, but not stop, drinking is not a candidate for disulfiram. Disulfiram should also be avoided in individuals with advanced liver disease.^162^

Naltrexone is the opioid antagonist described above that is used to treat opioid use disorder. Because it blocks some opioid receptors, naltrexone counteracts some of the pleasurable aspects of drinking.^154,159^ Unlike disulfiram, naltrexone does not interact with alcohol to produce a severe reaction.^163^ As noted before, naltrexone comes in two formulations: oral and extended-release injectable.

Many studies have examined the effectiveness of naltrexone in treating alcohol use disorders.^154^ Several research reviews have found that it reduces the risk of heavy drinking in patients who are abstinent for at least several days at the time treatment begins.^154,160^ However, as with disulfiram, medication compliance can be a problem with the oral formulation. Adherence to taking the medication increases under conditions where it is administered and observed by a trusted family member or when the extended-release injectable, which requires only a single monthly injection, is used.^164^ Naltrexone should not be prescribed to patients with acute hepatitis, renal failure, or liver failure.^162^

Acamprosate is a medication that normalizes the alcohol-related neurochemical changes in the brain glutamate systems and thereby reduces the symptoms of craving that can prompt a relapse to pathological drinking.^117^ Acamprosate has been found to be an effective medication when used concurrently with behavioral interventions and, as with other medications for alcohol use disorders, works best in motivated patients.^117,165^ Reviews show that acamprosate is effective in reducing relapse^166^ and effective when used to maintain abstinence from alcohol.^167^

### Behavioral Therapies

Behavioral therapies can be provided in individual, group, and/or family sessions in virtually all treatment settings.^47,56^ These structured therapies help patients recognize the impact of their behaviors – such as those dealing with stress or interacting in interpersonal relationships – on their substance use and ability to function in a healthy, safe, and productive manner. These therapies also teach and motivate patients in how to change their behaviors as a way to control their substance use disorders.^56^

For evidence-based behavioral therapies to be delivered appropriately, they must be provided by qualified, trained providers. Despite this, many counselors and therapists working in substance use disorder treatment programs have not been trained to provide evidence-based behavioral therapies, and general group counseling remains the major form of behavioral intervention available in most treatment programs.^168^ Unfortunately, despite decades of research, it cannot be concluded that general group counseling is reliably effective in reducing substance use or related problems.^169,170^

The following sections describe behavioral therapies that have been shown to be effective in treating substance use disorders. These therapies have been studied extensively, have a well-supported evidence base indicating their effectiveness, and have been broadly applied across many types of substance use disorders and across ages, sexes, and racial and ethnic groups.

Individual counseling is delivered in structured sessions to help patients reduce substance use and improve function by developing effective coping strategies and life skills.^85,171^ Individual counseling has been extensively studied in many specialty care settings but rarely within non-specialty settings. Most studies support the use of individual counseling as an effective intervention for individuals with substance use disorders.^117,169^ As indicated above, group counseling is a standard part of most substance use disorder treatments, but should primarily be used only in conjunction with individual counseling^171^ or other forms of individual therapy.^85^

#### Cognitive-Behavioral Therapy

The theoretical foundation for Cognitive-Behavioral Therapy (CBT) is that substance use disorders develop, in part, as a result of maladaptive behavior patterns and dysfunctional thoughts.^117^ CBT treatments thus involve techniques to modify such behaviors and improve coping skills by emphasizing the identification and modification of dysfunctional thinking.^117^ CBT is a short-term approach, usually involving 12 to 24 weekly individual sessions. These sessions typically explore the positive and negative consequences of substance use, and they use self-monitoring as a mechanism to recognize cravings and other situations that may lead the individual to relapse. They also help the individual develop coping strategies.^85^

CBT may be the most researched and evaluated of all the therapies for substance use disorders.^172,173^ Research suggests that self-monitoring and craving-recognition skills can be learned during CBT and that those skills continue to be employed by the individual after treatment has concluded.^85^ CBT interventions have been found to be quite effective, and outcomes are enhanced when CBT is combined with other behavioral and/or pharmacologic components of care.^174^

Research has shown that CBT is also an effective treatment for individuals with co-occurring mental disorders. Individuals with a substance use disorder and co-occurring mental disorder who received CBT had significantly improved outcomes on various measures of substance use and mental health symptoms as compared to those who did not receive CBT.^101,175,176^

#### Contingency Management

Behavior change involves learning new behaviors and changing old behaviors. Positive rewards or incentives for these changes can aid this process. Contingency management, which involves giving tangible rewards to individuals to support positive behavior change,^85^ has been found to be effective in treating substance use disorders.^177^ In this therapy, patients receive a voucher with monetary value that can be exchanged for food items, healthy recreational options (e.g., movies), or other sought-after goods or services when they exhibit desired behavior such as drug-free urine tests or participation in treatment activities.^85^ Clinical studies comparing voucher-based reinforcement to traditional treatment regimens have found that voucher-based reinforcement is associated with longer treatment engagement, longer periods of abstinence, and greater improvements in personal function.^177^ These positive findings, initially demonstrated with individuals with cocaine use disorders, have been reproduced in individuals with alcohol, opioid, and methamphetamine use disorders.^177^

Contingency management may be combined with other therapies or treatment components. For example, contingency management has been shown to improve outcomes for adults with cocaine dependence when added to CBT.^178^ Similarly, contingency management improves outcomes for young adults with marijuana dependence when included with Motivational Enhancement Therapy (described below) and CBT.^179^

#### Community Reinforcement Approach

Community Reinforcement Approach (CRA) Plus Vouchers is an intensive 24-week outpatient program that uses incentives and reinforcers to reward individuals who reduce their substance use.^85^ Individuals are required to attend one to two counseling sessions each week that emphasize improving relations, acquiring skills to minimize substance use, and reconstructing social activities and networks to support recovery.^85^ Individuals receiving this treatment are eligible to receive vouchers with monetary value if they provide drug-free urine tests several times per week.^85^ Research has demonstrated that CRA Plus Vouchers promotes treatment engagement and facilitates abstinence.^85^ Recent studies have also shown improvements in psychosocial functioning and abstinence among individuals who received CRA Plus Vouchers compared to those who received an intervention of standard care only.^180^

CRA without vouchers has been successfully adapted for adolescents. The Adolescent Community Reinforcement Approach (A-CRA) is a similar program targeting 12 to 22 year olds with substance use disorders. A-CRA, which has been implemented in outpatient and residential treatment settings, seeks to increase family, social, and educational and vocational supports to reinforce abstinence and recovery from substance use. The effectiveness of A-CRA has been supported in multiple randomized clinical trials with adolescents from different settings, sexes, and racial groups.^181,182^ Studies have found that A-CRA increased long-term abstinence from marijuana and alcohol and decreased frequency of other substance use.^182^

#### Motivational Enhancement Therapy

Motivational Enhancement Therapy (MET) is a counseling approach that uses motivational interviewing techniques to help individuals resolve any uncertainties they have about stopping their substance use. MET works by promoting empathy, developing patient awareness of the discrepancy between their goals and their unhealthy behavior, avoiding argument and confrontation, addressing resistance, and supporting self-efficacy^46^ to encourage motivation and change.^85,183^ The therapist supports the patient in executing the behaviors necessary for change and monitors progress toward patient-expressed goals.

MET has been shown to be an effective treatment in a range of populations and has demonstrated favorable outcomes such as reducing substance use and improving treatment engagement.^169^ As with other therapies reviewed, MET is often used concurrently with other behavioral interventions.^184^ However, the results of MET are mixed for people who use drugs such as heroin, cocaine, and nicotine, and for adolescents.^185,186^ The combination of MET and CBT has shown favorable results for adolescents for multiple substances.^181^

#### The Matrix Model

The Matrix Model is a structured, multi-component behavioral treatment that consists of evidence-based practices, including relapse prevention, family therapy, group therapy, drug education, and self-help, delivered in a sequential and clinically coordinated manner.^85^ The model consists of 16 weeks of group sessions held three times per week, which combine CBT, family education, social support, individual counseling, and urine drug testing.^187^

Several randomized controlled trials over the past 20 years have demonstrated that the Matrix Model is effective at reducing substance misuse and associated risky behaviors.^85^ For example, one study demonstrated the model's effectiveness in producing sustained reductions in sexual risk behaviors among individuals who use methamphetamines, thus decreasing their risk of getting or transmitting HIV.^188^ The Matrix Model has also been adapted to focus more on relationships, parenting, body image, and sexuality in order to improve women's retention in treatment and facilitate recovery.^189^

#### Twelve-Step Facilitation Therapy

Twelve-Step Facilitation (TSF), an individual therapy typically delivered in 12 weekly sessions, is designed to prepare individuals to understand, accept, and become engaged in Alcoholics Anonymous (AA), Narcotics Anonymous (NA), or similar 12-step programs.^190,191^ As discussed in the next chapter, 12-step programs and other mutual-aid groups are not themselves medical treatments but fall under the category of RSS. Well-supported evidence shows that TSF interventions are effective in a variety of ways:

- As a stand-alone intervention;^192-194^
- When integrated with other treatments, such as CBT;^190^
- As a distinct component of a multi-treatment package;^191^ and
- As a modular appendage to treatment.^195^

FOR MORE ON THIS TOPIC

See Chapter 5 - Recovery: The Many Paths to Wellness.

Some substance use disorder treatment programs that employ TSF also typically encourage AA or NA participation through group counseling.^123^ However, TSF is quite different from generic group counseling, not only because it is an individual therapy, but also because it involves a systematic set of sequential sessions focused on three key ideas:^85^

- Acceptance - realizing that their substance use is part of a disorder, that life has become unmanageable because of alcohol or drugs, that willpower alone will not overcome the problem, and that abstinence is the best alternative;
- Surrender - giving oneself to a higher power, accepting the fellowship and support structure of other recovering individuals, and following the recovery activities laid out by a 12-step program; and
- Active involvement in a 12-step program.

KEY TERMS

12-Step Program. A group providing mutual support and fellowship for people recovering from addictive behaviors. The first 12-step program was Alcoholics Anonymous (AA), founded in 1935; an array of 12-step groups following a similar model have since emerged and are the most widely used mutual aid groups and steps for maintaining recovery from alcohol and drug use disorders. It is not a form of treatment, and it is not to be confused with the treatment modality called TSF.

TSF has been effective in reducing alcohol use during the first month of treatment for individuals with alcohol use disorders, but these effects disappeared rapidly following treatment completion.^196^ In one study, alcohol-dependent women were randomly assigned to TSF, CBT, or a standard counseling group. The women who received TSF and CBT over 12 weeks both had better outcomes on perceived social support from friends and on social functioning than those in the counseling group, and the differences between those receiving TSF and CBT were minimal.^197^

In another study, a randomized controlled trial compared a CBT treatment program alone to the same treatment combined with TSF. TSF in addition to CBT increased AA involvement and days of abstinence over a 12-month follow-up period as compared to CBT alone.^190^ Statistical analysis showed the benefits of the TSF stemmed from its ability to increase AA participation in the period after treatment ended. Further, another randomized controlled trial of outpatients with severe alcohol use disorder evaluated a treatment that aimed to change people's social networks away from heavy drinkers and toward non-drinking individuals, including AA members.^194^ Those receiving the social network enhancement treatment had 20 percent more abstinent days and greater AA participation at 2-year follow-up than did patients assigned to receive standard case management. Again, AA participation and the number of abstinent friends in the social network were found to account for the treatment's effectiveness.^194^

Project MATCH, the largest study of alcohol use disorder treatment ever conducted, found that TSF increased rates of continuous abstinence and sustained remission at the same rates as two other evidenced-based treatments—CBT and MET. All three treatments reduced the quantity and frequency of alcohol use immediately after treatment. Further, relative to the CBT and MET treatment conditions, significantly more of the patients receiving TSF treatment maintained continuous abstinence in the year following treatment.^193^ The same pattern of results was also evident at follow-up 3 years later.^198^ Like the other studies discussed, data analysis showed that the effectiveness of the TSF treatment was based on its differential ability to increase post-treatment participation in AA.^196^

The first clinical trial of TSF for patients in treatment for stimulant use disorder was recently completed. Individuals randomized to TSF had higher rates of attending groups such as Crystal Meth Anonymous and higher rates of abstinence at follow-up as well.^199^

Given the common group and social orientation and the similar therapeutic factors operating across different mutual aid groups,^200-202^ participation in mutual aid groups other than AA might confer similar benefits at analogous levels of attendance.^203,204^ Yet systematic efforts to facilitate entry into non-12-step mutual aid groups have rarely been studied.^204^ One exception is a clinical trial evaluating SMART Recovery, a cognitive-behavioral, evidence-based mutual aid group. Patients in treatment for “heavy drinking” were randomly assigned to receive face-to-face SMART Recovery meetings or to an online Web meeting. Both groups showed approximately equal rates of post-treatment participation in SMART Recovery and in abstinence.^205^

#### Family Therapies

Mainstream health care has long acknowledged the benefits of engaging family and social supports to improve treatment adherence and to promote behavioral changes needed to effectively treat many chronic illnesses.^206^ This is also true for patients with substance use disorders. Studies of various family therapies have demonstrated positive findings for both adults and adolescents.^85^ Family therapies engage partners and/or parents and children to help the individual achieve positive outcomes based on behavior change. Several evidence-based family therapies have been evaluated.

Family behavior therapy (FBT) is a therapeutic approach used for both adolescents and adults that addresses not only substance use but other issues the family may also be experiencing, such as mental disorders and family conflict.^85^ FBT includes up to 20 treatment sessions that focus on developing skills and setting behavioral goals. Basic necessities are reviewed and inventoried with the client, and the family pursues resolution strategies and addresses activities of daily living, including violence prevention and HIV/AIDS prevention.^207^

Family therapies used specifically for treating substance use disorders in adolescents include Multi-Systemic Therapy (MST), Multi-Dimensional Family Therapy (MDFT), Brief Strategic Family Therapy (BSFT), and Functional Family Therapy (FFT).^85^ Most of these therapies consist of sessions that include the adolescent and at least one other family member, although MDFT uses a combination of both individual and family sessions.^85^ These interventions use different approaches, ranging from addressing antisocial behaviors (MST) and unfavorable influences (MDFT) on adolescents to identifying patterns of negative behaviors and interactions within the family (BSFT and FFT).^85^

Perhaps the most widely studied and applied family therapy has been Behavioral Couples Therapy (BCT). A cardinal feature of BCT is the “daily sobriety contract” between the affected patient and his/her spouse in which the patient states his or her intent not to drink or use drugs, and the spouse expresses support for the patient's efforts to stay abstinent. BCT also teaches communication and non-substance-associated positive activities for couples. Findings show that BCT produces more abstinence and better functioning relationships than typical individual-based treatment and that it also reduces social costs and intimate partner violence.^208^

Well-supported evidence demonstrates the effectiveness of substance use disorder therapies that engage the spouse or partner and the family in reducing substance use and/or misuse problems and addressing other issues, such as poor communication, neglect, conflict, and intimate partner violence. In a recent review of controlled studies with alcohol-dependent patients, marital and family therapy, and particularly behavioral couples therapy, was significantly more effective than individual treatments at inducing and sustaining abstinence; improving relationship functioning and reducing intimate partner violence; and reducing emotional problems of children.^209,210^ Similar findings have been shown with patients having opioid and cocaine use disorders^208,210^ and with gay and lesbian families.^210^

#### Tobacco Use Cessation Efforts in Substance Use Disorder Treatment Programs

People with mental and/or substance use disorders account for 40 percent of all cigarettes smoked in the United States.^211^ Many substance use disorder treatment facilities and programs have adopted tobacco-free policies and tobacco cessation programs. Research has shown that incorporating tobacco cessation programs into substance use disorder treatment does not jeopardize treatment outcomes^212^ and is associated with a 25 percent increase in the likelihood of maintaining long-term abstinence from alcohol and drug misuse.^213^

### Recovery Support Services

Recovery support services (RSS), provided by both substance use disorder treatment programs and community organizations, help to engage and support individuals in treatment, and provide ongoing support after treatment. These supportive services are typically delivered by trained case managers, recovery coaches, and/or peers. Specific supports include help with navigating systems of care, removing barriers to recovery, staying engaged in the recovery process, and providing a social context for individuals to engage in community living without substance use.^214^ RSS can be effective in promoting healthy lifestyle techniques to increase resilience skills, reduce the risk of relapse, and help those affected by substance use disorders achieve and maintain recovery.^56^

FOR MORE ON THIS TOPIC

See Chapter 5 - Recovery: The Many Paths to Wellness.

Individuals who participate in substance use disorder treatment and RSS typically have better long-term recovery outcomes than individuals who receive either alone. Further, active recovery and social supports, both during and following treatment, are important in maintaining recovery.^214^ This has also been demonstrated for adolescents; the combination of behavioral treatments with assertive continuing care has yielded positive results for this age group, beyond treatment alone.^215^

## Emerging Treatment Technologies

Technological advancements are changing not only the face of health care generally, but also the treatment of substance use disorders. In this regard, approximately 20 percent of substance use disorder treatment programs have adopted electronic health record (EHR) systems. With the growing adoption of EHRs, individuals and their providers can more easily access and share treatment records to improve coordination of care.^216^ In turn, information sharing through EHRs can lead to improved quality and efficiency of service delivery, reduced treatment gaps, and increased cost savings to health systems.

KEY TERMS

Telehealth. The use of digital technologies such as EHRs, mobile applications, telemedicine, and web-based tools to support the delivery of health care, health-related education, or other health-related services and functions.^1^

Telemedicine. Two-way, real-time interactive communication between a patient and a physician or other health care professional at a distant site. Telemedicine is a subcategory of telehealth. Telemedicine refers specifically to remote clinical services, whereas telehealth can include remote non-clinical services such as provider training, administrative meetings, and continuing medical education, and patient-focused technologies, in addition to clinical services.

The use of telehealth to deliver health care, provide health information or education, and monitor the effects of care, has also rapidly increased.^217^ Telehealth can be facilitated through a variety of media, including smartphones, the Internet, videoconferencing, wireless communication, and streaming media. It offers alternative, cost-effective care options for individuals living in rural or remote areas or when physically travelling to a health care facility poses significant challenges.

Technology-based interventions offer many potential advantages. They can increase access to care in underserved areas and settings; free up time so that service providers can care for more clients; provide alternative care options for individuals hesitant to seek in-person treatment; increase the chances that interventions will be delivered as they were designed and intended to be delivered; and decrease costs.^218-222^ Further, studies show that most individuals already have access to the necessary tools to engage in technology-based care; about 92 percent of United States adults own a cell phone^223^ and 85 percent use the Internet.^224^

Research on the effectiveness of technology-assisted care within substance use disorder treatment focuses on three main applications: (1) technology as an add-on to enhance standard care; (2) technology as a substitute for a portion of standard care; and (3) technology as a replacement for standard care.^221^ The current evidence base of technology-based interventions for substance use disorder treatment is limited, though it is growing.^221,225-227^ For this reason, these technologies can only be considered “promising” at this time. Table 4.5 shows the state of evidence supporting innovative technology-assisted interventions, several of which are discussed in the Electronic Treatment Interventions and Electronic Clinical and Recovery Support Tools sections.

Table 4.5 Examples of Technology-Assisted Interventions

Intervention | Intervention Overview | Sample (at pretest) /Ethnicity/ Setting Design | Summary/Results | Source
Addiction–Comprehensive Health Enhancement Support System (A-CHESS) | Smartphone-based application offering monitoring, information, communication, and support services. | N = 349 individuals with alcohol dependence entering treatment at residential programs Varied settings, multiethnic RCT | At 4-, 8- and 12-month follow-up, intervention group reported significantly fewer risky drinking days (1.39 vs. 2.75 days on average) and a higher likelihood of consistent abstinence (51.9% vs. 39.6%) as compared to the control group. | Gustafson et al., (2014)^228^
CBT4CBT | Six-module computer-based cognitive behavioral therapy training. | N = 101 cocaine-dependent individuals maintained on methadone Urban, multiethnic RCT | After completing an 8-week program, participants who received the intervention were significantly more likely to attain 3 or more consecutive weeks of abstinence from cocaine than were participants who did not receive the program (36% vs. 17%). 6-month follow-up data indicated continued improvement for intervention group. | Carroll et al., (2014)^229^
HealthCall | 60 days of patient automated telephone interactive voice response (IVR) calls to self-monitor alcohol-and other health-related behaviors as adjunct to motivational interviewing. | N = 258 HIV-positive individuals reporting alcohol misuse Urban HIV primary care clinic, multiethnic RCT | After 60 days, members of intervention group with alcohol dependence reported significantly fewer drinks per drinking day as compared to control group (3.55 vs. 6.07). Lower rates of drinks per drinking day among intervention group maintained at 12-month follow-up. | Hasin et al., (2013)^230^
Reduce Your Use | Self-guided web-based treatment program for cannabis use disorder based on cognitive, motivational, and behavioral principles. | N = 225 individuals looking to reduce or cease cannabis use Varied settings RCT | After 6 weeks, the intervention group reported significantly fewer days of cannabis use in the past month, significantly lower past-month quantity of cannabis use, and significantly fewer symptoms of cannabis abuse compared to the control group. Similar results at 3-month follow-up. | Rooke et al., (2013)^231^
Self-Help for Alcohol and other Drug Use and Depression (SHADE) | Nine sessions of computer-delivered motivational interviewing and cognitive behavior therapy with brief therapist assistance. | N = 274 individuals with comorbid depression and alcohol/cannabis misuse Community-based, Australia RCT | At 3-month follow-up, the intervention group that received computer-delivered care achieved 4 times the reduction in alcohol consumption compared to the control group, and 2.5 times the reduction of the group who received therapist-delivered care. | Kay-Lambkin et al., (2011)^232^
Therapeutic Education System (TES) | 62 computer-interactive modules teaching skills for achieving and maintaining abstinence, as well as prize-based motivational incentives based on abstinence and treatment adherence. | N = 507 adult men and women Outpatient addiction treatment programs RCT | Compared to the control group, those receiving TES reduced dropout from treatment (Hazard Ratio=0.72) and increased abstinence (Odds Ratio=1.62). | Cambell et al., (2015)^233^

Note: RCT = randomized controlled trial.

### Electronic Assessments and Early Intervention

Several studies have been conducted on technology-assisted screening, assessment, and brief intervention for substance use disorders. Many of these studies focus on Internet-based assessments and brief interventions for at-risk, college-age populations. Examples of evaluated tools include the Check Your Drinking screener,^234^ electronic alcohol screening and brief intervention (e-SBI),^235^ Drinker's Check-up,^236^ Alcohol electronic Check-Up to Go (e-CHUG,)^237^ and Marijuana eCHECKUP TO GO.^238^ Other studies assessed interventions that can be implemented in general health care settings, including Project QUIT, a brief intervention in a primary care setting that also includes follow-up coaching calls for individuals who have been identified through screening as engaging in risky drug use,^50^ and use of kiosks in emergency departments to screen for alcohol and drug use.^239^ In the latter study, patients in the emergency department were found to be significantly more likely to disclose their substance use at a kiosk compared to a health care professional or other interviewer. Other studies focus on telephone-based assessments and brief interventions related to alcohol and drug use, including DIAL,^240^ and a telephone-based monitoring and brief counseling intervention.^241^ Preliminary evidence shows that Web- and telephone-based assessments and brief interventions are superior to no treatment in reducing substance use, and often result in similar or improved outcomes when compared to alternative brief intervention options.^236,241-247^

### Electronic Treatment Interventions

A larger pool of research studies has assessed the effectiveness of substance use disorder treatment approaches (largely outpatient) that incorporate Web- and telephone-based technology. These interventions focus on a wider range of substances, including alcohol (e.g., Drinking Less,^248^ HealthCall^230^), opioids (e.g., Therapeutic Education System,^226^ CBT4CBT^229^), and marijuana (e.g., Reduce Your Use,^231^ SHADE^232^), and target various subpopulations, including veterans and individuals with co-occurring disorders and other chronic illnesses.^230,232,249^

Many of these technology-enhanced treatment interventions are Web-based versions of evidence-based, in-person treatment components such as CBT and MET. Early research suggests the value of applying Web-based treatment approaches for moderate levels of substance misuse and for individuals who may not otherwise seek face-to-face treatment.^221,250^ Among studies evaluating Web-based intervention support as an add-on to standard in-person treatment, preliminary evidence shows reduced substance use, better retention, and higher motivation to change among the intervention group.^229,233,251,252^ One study explored replacing traditional in-person CBT with a Web-based version and found at least equivalent outcomes among the intervention group, indicating great potential for these Web-based interventions to broaden the dissemination of evidence-based treatments.^232^

Recent studies of telephone-based interventions as adjuncts to or replacements for standard care interventions showed similarly promising results. For example, one study explored the effect of adding daily self-monitoring calls to an interactive voice response technology system with personalized feedback and compared it to standard motivational enhancement practice. Study results showed that those who received the intervention reduced the number of drinks they had on the days they did drink.^230^

### Electronic Clinical and Recovery Support Tools

Several studies have examined the application of technology-assisted tools to RSS. In general, Web- and telephone-based recovery support tools focus on providing remote support to individuals following substance use disorder treatment. Examples of e-recovery support tools include: A-CHESS, a smartphone application that provides monitoring, information, communication, and support services to patients, including ways for individuals and counselors to stay in contact;^228^ and MORE, a Web-based recovery support program that delivers assessments, clinical content, and access to recovery coaching support online.^253^ Preliminary evidence shows that technology-assisted recovery support approaches may be effective in helping individuals to maintain their recovery.^221,228,253^ In 2014, a study found that OTP participants receiving ongoing counseling services through Web-based videoconferencing technology experienced comparable rates of decreased drug use and program attendance as did individuals receiving in-person care.^227^

## Considerations for Specific Populations

### Culturally Competent Care

A variety of treatment approaches have been developed to address the needs of individuals with substance use disorders. However, disparities exist in the outcomes and effectiveness of substance use treatment for different populations.^109,254^ Research has shown that treatment needs can differ across various populations,^255,256^ suggesting that treatment interventions should be individually tailored and incorporate culturally competent and linguistically appropriate practices relevant to specific populations and subpopulation groups.^257^

### Racial and Ethnic Groups

A study examining a culturally sensitive substance use disorder intervention program targeted at Hispanic or Latino and Black or African American adolescents called Alcohol Treatment Targeting Adolescents in Need (ATTAIN) found significant reductions in alcohol and marijuana use for all racial and ethnic groups.^258^ Cultural factors, including discrimination, acculturation, ethnic pride, and cultural mistrust, were associated with the pre-intervention levels of alcohol and drug use. The study concluded that accounting for these factors when tailoring a substance use disorder intervention is critical to meeting the needs of the community it is aiming to serve.

Many of the interventions developed for substance use disorder treatment services in general have been evaluated in populations that included Black or African American patients, and many of these interventions are as effective for Black or African American patients as they are for White patients.^259,260^ Some motivational interventions that are aligned with the cultural values of the population have been found to reduce substance use among Blacks or African Americans.^27,257^

Dialectical Behavior Therapy (DBT) is an evidence-based therapy that teaches a skill called mindfulness. Multiple research studies have noted that mindfulness, an attentional exercise originally developed in Buddhist cultures, is potentially useful in helping people gain mastery over substance cravings.^261^ A study examining patients in a substance use disorder residential treatment center that incorporated DBT with specific cultural, traditional, and spiritual practices for American Indian or Alaska Native adolescents found that 96 percent of the adolescents in their sample either “recovered” or “improved.”^262^ Treatment included all aspects of comprehensive DBT and included consultation with tribal leaders from the governing body and a medicine man/spiritual counselor from a local tribe.

Asian patients tend to enter treatment with less severe substance misuse problems than do members of other racial or ethnic groups,^263^ place less value on substance use disorder treatment, and are less likely to use such services.^264^ Studies on Asians and Native Hawaiians and Pacific Islanders have identified culturally specific barriers and facilitators to entering and completing substance use treatment (e.g., family, peers, shame, and involvement in the criminal justice system).^265^ Assessing patient experience of shame is an important step when providing substance use disorder treatment to Asian patients because shame and humiliation can be significant barriers to treatment engagement for this population.^266^

Combining Evidence-based Care with Traditional, Spiritual, and Cultural Beliefs

“The results demonstrated by the outcome data far exceeded expectations. DBT has dramatically improved the care of adolescents at our facilities. A serendipitous benefit has been the enhancement of the relationship with the multiplicity of referral sources. Our tribal partners have commented positively on the integration of DBT with those traditional, cultural, and spiritual practices that are common to the many tribal nations.”

– Rear Admiral Vincent Berkley, USPHS, Retired Medical Director, Youth Treatment Centers of Arizona and Nevada

##### Agency or Organization

Desert Visions Youth Wellness Center (Desert Visions), Indian Health Service, Sacaton, Arizona

##### Purpose

Desert Visions is a federally-operated adolescent residential center whose purpose is to provide substance use and behavioral health treatment to American Indians and Alaska Natives. Desert Visions offers a multi-disciplinary treatment that includes bio-psychosocial, health, education, and cultural activities. Desert Visions uses Dialectical Behavior Therapy (DBT) as the treatment modality, and clients are taught to use the DBT skills to improve their quality of life.

##### Goals

- Provide holistic care and treatment for the physical, spiritual, and emotional needs of American Indian and Alaska Native adolescents.
- Provide superior outcomes in treating substance use/co-occurring disorders.
- Utilize the DBT skill of mindfulness to allow for the introduction of cultural, spiritual, and traditional practices into treatment while still maintaining fidelity to this evidence-based approach. In essence, the goal of using DBT is to combine the best of “Western-Based” interventions with traditional American Indian/Alaska Native interventions.

##### Outcomes

A 3-year program/statistical review of outcome data found that of 229 patients who were enrolled in the treatment program:

- 201 met the criteria for clinically significant change, (i.e., “recovered” or “reliable change” or “improved”) and 10 showed no change.
- None of the youth in treatment deteriorated during the treatment period.
- The findings represent a first investigation of the use of DBT within American Indian and Alaska Native populations.

### Lesbian, Gay, Bisexual, and Transgender Populations

Lesbian, gay, bisexual, and transgender (LGBT) populations often enter treatment with more severe substance misuse problems,^267^ have a greater likelihood of experiencing a substance use disorder in their lifetime, and initiate alcohol consumption earlier than heterosexual clients;^268^ thus, developing effective treatment programs that address the specific needs of these populations is critical. For example, the 2013 National Health Interview Survey, conducted by the U.S. Census Bureau, found that a higher percentage of LGBT adults, aged 18 to 64, had five or more drinks on one day in the past year compared to heterosexual adults.^269^ Research has also shown that LGB adolescents report higher rates of substance use compared to heterosexual youth; on average substance use among LGB youth was 190 percent higher than for heterosexual youth, 340 percent higher for bisexual youth, and 400 percent higher for lesbians and bisexual females.^270^ Treatment programs with specialized groups for gay and bisexual clients have shown better outcomes for men compared to gay and bisexual men in non-specialized programs.^113^ According to one analysis, a significant minority of the nation's substance use disorder treatment agencies indicated that they offer treatment services tailored to LGBT populations, although only a small portion (7.4 percent) offered a service that they could identify as an LGBT-specialized service.^271^

Research has shown that treatment providers should be knowledgeable about sexuality, sexual orientation, and unique aspects of LGBT developmental and social experiences.^272^ For example, factors such as transphobia or homophobia (both internal and societal), violence, family issues, and social isolation, among other problems, may need to be addressed within the substance use disorder treatment environment for transgender people.^273^ It is also important to consider the types of treatment that have been shown effective with the LGBT population. Motivational interviewing, social support therapy, contingency management, and CBT have all demonstrated effectiveness specifically for gay or bisexual men with a substance use disorder.^272^

### Veterans

Being a veteran or an active member of the military is a unique way of life that involves experiences and sacrifices by the service member and the member's family. Military service members, veterans, and their families have needs unlike other individuals that require culturally competent approaches to treatment and services. Veterans report high rates of substance misuse; between 2004 and 2006, 7.1 percent of all veterans met the criteria for a substance use disorder.^274^ Studies of female veterans have shown that between 4 and 37 percent of veterans reported alcohol misuse, 7 to 25 percent reported binge drinking, and between 3 and 16 percent reported substance use disorders.^275^ Much of the literature on substance use in the military examines the relationship between post-traumatic stress disorder (PTSD) and alcohol and drug use. For example, a large study examined improvement in substance use outcomes among 12,270 veterans who were diagnosed with PTSD and a substance use disorder and treated in specialized intensive veterans' treatment programs. The study found that treatment in longer-term programs, with prescribed psychiatric medication and planned participation in program reunions for post-discharge support, were all associated with improved outcomes.^276^ Reductions in substance use were also associated with improvements in PTSD symptoms and violent behavior. The findings suggested that intensive treatment combined with proper discharge planning for veterans with severe PTSD and a substance use disorder may result in better outcomes than traditional substance use disorder treatment. A study among homeless veterans with a diagnosis of a substance use disorder as well as a mental disorder found that those who took part in a low-intensity wrap-around intervention showed improvements in a number of substance use, mental health, and behavioral health outcomes from the beginning of the study to follow-up 12 months later.^277^

### Criminal Justice Populations

It has been estimated that half of the United States prison population has an active substance use disorder.^278^ Many incarcerated individuals will experience a lower tolerance for substances due to abstinence while in prison; upon release, many will return to dangerous use levels, not realizing their tolerance is diminished.^279^ This is particularly important as it raises the risk of opioid overdose deaths after release from incarceration; one study found that 14.8 percent of all former prisoner deaths from 1999 to 2009 were related to opioids.^280^ There is typically insufficient pre-release counseling and post-release follow-up provided to this population to reduce these risks.^281^

In a randomized controlled trial of methadone maintenance for prisoners, participants were randomly assigned to counseling with passive referral to methadone maintenance treatment (MMT) after release, counseling with transfer to MMT, or counseling with pre-release MMT. Prisoners who received counseling and MMT in prison prior to release and continued with community-based MMT after release were significantly less likely to use opioids and engage in criminal activity post-release.^282^ Increased access to opioid agonist maintenance may positively impact the needs of substance use disorders among incarcerated individuals.^283^

Another randomized trial assigned some participants to extended-release naltrexone treatment and others to usual treatment, consisting of brief counseling and referrals to community treatment programs. Those who received extended-release naltrexone had a lower rate of relapse (43 percent vs. 64 percent), and a higher rate of opioid-negative urine samples (74 percent vs. 56 percent), and the average time between treatment and relapse was found to be longer—10.5 weeks, compared with 5.0 weeks for those who received usual treatment. Importantly, positive effects diminished after treatment with extended-release naltrexone was discontinued.^284^

### Drug Courts

Drug courts are a diverse group of specialized programs that focus on adult or juvenile offenders, as well as parents under child protective supervision who have substance use-related disorders.^285^ Drug courts provide treatment and other services, overseen by a judge, in lieu of being processed through the traditional justice system. By 2015, more than 3,400 drug courts were in operation across the United States.^285^ An estimated 55,000 defendants per year participate in adult drug courts,^286,287^ with each court serving a caseload of approximately 50 individuals each year.^288^ These interventions seek to harness the coercive power of the criminal justice system to persuade drug-involved offenders to cease their problematic drug use.

Existing research, including randomized controlled trials, have found positive effects of drug courts, including high rates of treatment completion and reduced rates of recidivism, incarceration, and subsequent drug use.^288-291^ Reviews of these evaluations have concluded that the average effect of adult drug court participation is analogous to a drop in recidivism from 50 percent to 38 percent, and that this effect lasts up to 3 years.^289^ Evaluations of driving under the influence (DUI) drug courts generally find similar reductions as adult drug courts and substantially smaller effects than are found in juvenile drug courts.^292^ Larger reductions in recidivism were found in adult drug courts that had high graduation rates and that accepted only nonviolent offenders, suggesting that this intervention may be more effective among that segment of the substance-using population.

Despite the rapid expansion of drug courts, the number of defendants who pass through such programs remains a small proportion of the more than 1 million offenders with substance use disorders who pass through the United States criminal justice system each year. Capacity constraints provide the most important limitation.^286^

Drug court programs require random drug tests and other monitoring measures. Required abstinence involves making sanctions certain and immediate. Hawaii's Opportunity Probation with Enforcement (HOPE) program has implemented coerced abstinence for the entire probation population. Promising results of a randomized trial have sparked interest in broader replication.^293^ Observed recidivism rates were dramatically lower than for the prior probation population, and the treatment group was incarcerated for roughly half as many days as the control group. Interventions such as HOPE do not necessarily involve substance use disorder treatment; this reflects the reality that many drug-involved offenders do not meet the criteria for substance use disorders. For many individuals, regular monitoring, alongside the adverse consequences of a failed urine test, provide powerful motivation to abstain.^294^

A further example is the 24/7 Sobriety Project (24/7), a South Dakota innovative program to supervise individuals who were arrested in connection with alcohol-related offenses. It addresses problem drinking by imposing close monitoring, followed by swift, certain, yet modest sanctions when there is evidence of renewed alcohol use. Under 24/7, problem drinkers rearrested for DUI and selected other alcohol-related violations were subject to intensive monitoring and sanctions. As a condition of bail, participants were required to take morning and evening breathalyzer tests or wear continuous alcohol-monitoring bracelets. Between 2005 and 2010, 24/7 participants were ordered to take approximately 3.7 million breathalyzer tests, and achieved a pass rate of approximately 99.3 percent.^295^ A RAND Corporation program evaluation found that 24/7 tangibly improved public safety in counties where the program was implemented at scale.^295^ In counties where the number of 24/7 participants reached one-quarter of DUI arrests, the intervention was associated with a significant reduction in repeat DUI and intimate partner violence arrests. Similar results have been replicated in Montana.^296^

## Recommendations for Research

Although the field of treatment for substance use disorders has made substantial progress, additional types of research are needed. Research involving early interventions and various components of treatment must move from rigorously controlled trials to natural delivery settings and a broader mix of patient types. Because rigorously controlled trials must focus on specific diagnoses and carefully characterized patient types, it is often the case that the samples used in these trials are not representative of the real-world populations who need treatment. For example, many opioid medication trials involve “opioid-only” populations, whereas in practice most patients with opioid use disorders also have alcohol, marijuana, and/or cocaine use disorders. Rigorously controlled trials are necessary to establish efficacy, but interventions that seem to be effective in these studies too often cannot be implemented in real-world settings because of a lack of workforce training, inadequate insurance coverage, and an inability to adequately engage the intended patient population.

As has been documented in several chapters within this Report, the great majority of patients with substance use disorders do not receive any form of treatment. Nonetheless, many of these individuals do access primary or general medical care in community clinics or school settings and research is needed to determine the availability and efficacy of treatment in these settings and to identify ways in which access to treatment in these settings could be improved. The current failure to acknowledge and address substance use disorders in these settings has reduced the quality and increased the costs of health care. Moreover, access and referral to specialty substance use disorder care from primary care settings is neither easy nor quick. Better integration between primary care and specialty care and additional treatment options within primary care are needed. Primary care physicians need to be better prepared to identify, assist, and refer patients, when appropriate. If treatment is delivered in primary care, it should be practical for delivery within these settings and attractive, engaging, accessible and affordable for affected patients.

Buprenorphine or naloxone treatment for opioid misuse should also be available in emergency departments.^297^ Here, the goals of treatment would be the reduction of substance use combined with better engagement in and adherence to treatment for any associated medical illness. Therefore, treatment research outside of traditional substance use disorder treatment programs is needed.

As of June 2016, four states, plus the District of Columbia, have legalized recreational marijuana, and many more have permitted medical marijuana use. The impact of the changes on levels of marijuana and other drug and alcohol use, simultaneous use, and related problems such as motor vehicle crashes and deaths, overdoses, hospitalizations, and poor school and work performance, must be evaluated closely. Accurate and practical marijuana screening and early intervention procedures for use in general and primary care settings are needed. Not only must it be determined which assessment tools are appropriate for the various populations that use marijuana, but also which treatments are generalizable from research to practice, especially in primary care and general mental health care settings.

Current research suggests that it is useful to educate and train first responders, peers, and family members of those who use opioids to use naloxone to prevent and reverse potential overdose-related deaths. However, more research is needed to identify strategies to encourage the subsequent engagement of those who have recovered from overdose into appropriate treatment. In this work, it will be important to consider contextual factors such as age, gender identity, race and ethnicity, sexual orientation, economic status, community resources, faith beliefs, co-occurring mental or physical illness, and many other personal issues that can work against the appropriateness and ultimately the usefulness of a treatment strategy.

Opioid agonist therapies are effective in stabilizing the lives of individuals with severe opioid use disorders. However, many important clinical and social questions remain about whether, when, and how to discontinue medications and related services. This is an important question for many other areas of medicine where maintenance medications are continued without significant change and often without attention to other areas of clinical progress.

At the same time, it is clear from many studies over the decades that detoxification following an arbitrary maintenance time period (e.g., 90 days, 180 days), or performed without continuing supports, is rarely effective in disengaging patients from opioid use disorders and may lead to relapse and overdose. Thus, more research is needed to explore if, when, and how patients can be transitioned from MAT to non-medication status within the context of “personalized medicine,” to provide both patients and clinical staff appropriate therapeutic guidance.

Regarding personalized medicine, research is needed on how to implement multidisciplinary, collaborative, and patient-centered care for persons with opioid use disorders and chronic pain, in a manner effectively treating both diseases together with any psychiatric comorbidities that may undermine recovery. Precision medicine research is also needed on how to individually tailor such interventions to optimize care management for patient groups in which there is overlap between pain-related psychological distress and stress-related opioid misuse.^298^

## References

1 HealthIT.gov. (2014). What is telehealth? How is telehealth different from telemedicine?.
2 Medina J. (2015). Symptoms of substance use disorders (Revised for DSM-5).
3 Substance Abuse and Mental Health Services Administration. (2015). Behavioral health treatments and services.
4 Evashwick C. (1988). Creating the continuum of care. Health Matrix.
5 Rieckmann T, Kovas AE, Rutkowski BA. (2010). Adoption of medications in substance abuse treatment: Priorities and strategies of single state authorities. Journal of Psychoactive Drugs.
6 Udo T, Vasquez E, Shaw BA. (2015). A lifetime history of alcohol use disorder increases risk for chronic medical conditions after stable remission. Drug and Alcohol Dependence.
7 Kline-Simon AH, Weisner C, Sterling S. (2016). Point prevalence of co-occurring behavioral health conditions and associated chronic disease burden among adolescents. Journal of the American Academy of Child & Adolescent Psychiatry.
8 Puddy RW, Wilkins N. (2011). Understanding evidence Part 1: Best available research evidence A guide to the continuum of evidence of effectiveness.
9 Compton WM, Thomas YF, Stinson FS, Grant BF. (2007). Prevalence, correlates, disability, and comorbidity of DSM-IV drug abuse and dependence in the United States: Results from the national epidemiologic survey on alcohol and related conditions. Archives of General Psychiatry.
10 Hasin DS, Stinson FS, Ogburn E, Grant BF. (2007). Prevalence, correlates, disability, and comorbidity of DSM-IV alcohol abuse and dependence in the United States: Results from the National Epidemiologic Survey on Alcohol and Related Conditions. Archives of General Psychiatry.
11 Ettner SL, Huang D, Evans E, Ash DR, Hardy M, Jourabchi M, Hser YI. (2006). Benefit-cost in the California treatment outcome project: Does substance abuse treatment “pay for itself”?. Health Services Research.
12 McLellan AT, Lewis DC, O'Brien CP, Kleber HD. (2000). Drug dependence, a chronic medical illness: Implications for treatment, insurance, and outcomes evaluation. JAMA.
13 Pasareanu AR, Opsal A, Vederhus J, Kristensen Ø, Clausen T. (2015). Quality of life improved following in-patient substance use disorder treatment. Health and Quality of Life Outcomes.
14 Garner BR, Scott CK, Dennis ML, Funk RR. (2014). The relationship between recovery and health-related quality of life. Journal of Substance Abuse Treatment.
15 Tracy EM, Laudet AB, Min MO, Kim H, Brown S, Jun MK, Singer L. (2012). Prospective patterns and correlates of quality of life among women in substance abuse treatment. Drug and Alcohol Dependence.
16 Sobell MB, Sobell LC. (2005). Guided self-change model of treatment for substance use disorders. Journal of Cognitive Psychotherapy.
17 Center for Substance Abuse Treatment. (1999). Brief interventions and brief therapies for substance abuse.
18 American Society of Addiction Medicine. (2001). ASAM patient placement criteria for the treatment of substance-related disorders.
19 Center for Behavioral Health Statistics and Quality. (2016). Results from the 2015 National Survey on Drug Use and Health: Detailed tables.
20 Agerwala SM, McCance-Katz EF. (2012). Integrating screening, brief intervention, and referral to treatment (SBIRT) into clinical practice settings: A brief review. Journal of Psychoactive Drugs.
21 Manuel JK, Satre DD, Tsoh J, Moreno-John G, Ramos JS, McCance-Katz EF, Satterfield JM. (2015). Adapting screening, brief intervention, and referral to treatment for alcohol and drugs to culturally diverse clinical populations. Journal of Addiction Medicine.
22 Harris SK, Knight JR. (2014). Putting the screen in screening: Technology-based alcohol screening and brief interventions in medical settings. Alcohol Research: Current Reviews.
23 Benningfield MM, Riggs P, Stephan SH. (2015). The role of schools in substance use prevention and intervention. Child and Adolescent Psychiatric Clinics of North America.
24 O'Donnell A, Anderson P, Newbury-Birch D, Schulte B, Schmidt C, Reimer J, Kaner E. (2014). The impact of brief alcohol interventions in primary healthcare: A systematic review of reviews. Alcohol and Alcoholism.
25 Schmidt CS, Schulte B, Seo HN, Kuhn S, A OD, Kriston L, Reimer J. (2016). Meta-analysis on the effectiveness of alcohol screening with brief interventions for patients in emergency care settings. Addiction.
26 Madras BK, Compton WM, Avula D, Stegbauer T, Stein JB, Clark HW. (2009). Screening, brief interventions, referral to treatment (SBIRT) for illicit drug and alcohol use at multiple healthcare sites: Comparison at intake and 6 months later. Drug and Alcohol Dependence.
27 Bernstein J, Bernstein E, Tassiopoulos K, Heeren T, Levenson S, Hingson R. (2005). Brief motivational intervention at a clinic visit reduces cocaine and heroin use. Drug and Alcohol Dependence.
28 Fuster D, Cheng DM, Wang N, Bernstein JA, Palfai TP, Alford DP, Saitz R. (2015). Brief intervention for daily marijuana users identified by screening in primary care: A subgroup analysis of the ASPIRE randomized clinical trial. Substance Abuse.
29 Saitz R. (2014). Screening and brief intervention for unhealthy drug use: Little or no efficacy. Frontiers in Psychiatry.
30 Estee S, He L, Mancuso D, Felver B. (2006). Medicaid cost outcomes.
31 Levy SJ, Williams JF, Committee on Substance Use and Prevention. (2016). Substance use screening, brief intervention, and referral to treatment. Pediatrics.
32 Levy SJ, Kokotailo PK. (2011). Substance use screening, brief intervention, and referral to treatment for pediatricians. Pediatrics.
33 Coble YD, Estes EH, Head CA, Karlan MS, Kennedy WR, Numann PJ, Strong JP. (1993). Confidential health services for adolescents. JAMA.
34 Canfield SE, Dahm P. (2011). Rating the quality of evidence and the strength of recommendations using GRADE. World Journal of Urology.
35 Committee on Health Care for Underserved Women. (2011). At-risk drinking and alcohol dependence: Obstetric and gynecologic implications. Obstetrics & Gynecology.
36 Shapiro B, Coffa D, McCance-Katz EF. (2013). A primary care approach to substance misuse. American Family Physician.
37 Center for Substance Abuse Treatment. (1999). Chapter 2—Brief interventions in substance abuse treatment. Brief interventions and brief therapies for substance abuse.
38 McNeely J, Cleland CM, Strauss SM, Palamar JJ, Rotrosen J, Saitz R. (2015). Validation of self-administered single-item screening questions (SISQs) for unhealthy alcohol and drug use in primary care patients. Journal of General Internal Medicine.
39 McNeely J, Strauss SM, Saitz R, Cleland CM, Palamar JJ, Rotrosen J, Gourevitch MN. (2015). A brief patient self-administered substance use screening tool for primary care: Two-site validation study of the Substance Use Brief Screen (SUBS). The American Journal of Medicine.
40 Clark DB, Martin CS, Chung T, Gordon AJ, Fiorentino L, Tootell M, Rubio DM. (2016). Screening for underage drinking and Diagnostic and Statistical Manual of Mental Disorders, 5th Edition alcohol use disorder in rural primary care practice. The Journal of Pediatrics.
41 Smith PC, Schmidt SM, Allensworth-Davies D, Saitz R. (2009). Primary care validation of a single-question alcohol screening test. Journal of General Internal Medicine.
42 Levy S, Dedeoglu F, Gafin JM, Garvey KC, Harstad E, MacGinnitie A, Wisk LE. (2016). A screening tool for assessing alcohol use risk among medically vulnerable youth. PLoS One.
43 National Institute on Drug Abuse. (2015). Chart of evidence-based screening tools for adults and adolescents.
44 Miller WR, Rollnick S. (2012). Motivational interviewing: Helping people change.
45 Lundahl B, Moleni T, Burke BL, Butters R, Tollefson D, Butler C, Rollnick S. (2013). Motivational interviewing in medical care settings: A systematic review and meta-analysis of randomized controlled trials. Patient Education and Counseling.
46 Center for Substance Abuse Treatment. (1999). Chapter 3—Motivational interviewing as a counseling style. Enhancing motivation for change in substance abuse treatment.
47 National Quality Forum. (2005). Evidence-based treatment practices for substance use disorders: Workshop proceedings.
48 Roy-Byrne P, Bumgardner K, Krupski A, Dunn C, Ries R, Donovan D, Graves MC. (2014). Brief intervention for problem drug use in safety-net primary care settings: A randomized clinical trial. JAMA.
49 Saitz R, Palfai TP, Cheng DM, Alford DP, Bernstein JA, Lloyd-Travaglini CA, Samet JH. (2014). Screening and brief intervention for drug use in primary care: The ASPIRE randomized clinical trial. JAMA.
50 Gelberg L, Andersen RM, Afifi AA, Leake BD, Arangua L, Vahidi M, Fleming MF. (2015). Project QUIT (Quit Using Drugs Intervention Trial): A randomized controlled trial of a primary care-based multi-component brief intervention to reduce risky drug use. Addiction.
51 Yuma-Guerrero PJ, Lawson KA, Velasquez MM, von Sternberg K, Maxson T, Garcia N. (2012). Screening, brief intervention, and referral for alcohol use in adolescents: A systematic review. Pediatrics.
52 Mitchell SG, Gryczynski J, O'Grady KE, Schwartz RP. (2013). SBIRT for adolescent drug and alcohol use: Current status and future directions. Journal of Substance Abuse Treatment.
53 Sterling S, Kline-Simon AH, Satre DD, Jones A, Mertens J, Wong A, Weisner C. (2015). Implementation of screening, brief intervention, and referral to treatment for adolescents in pediatric primary care: A cluster randomized trial. JAMA Pediatrics.
54 Ozechowski TJ, Becker SJ, Hogue A. (2016). SBIRT-A: Adapting SBIRT to maximize developmental fit for adolescents in primary care. Journal of Substance Abuse Treatment.
55 Satre DD, Campbell CI, Gordon NP, Weisner C. (2010). Ethnic disparities in accessing treatment for depression and substance use disorders in an integrated health plan. The International Journal of Psychiatry in Medicine.
56 Center for Health Information and Analysis. (2015). Access to substance use disorder treatment in Massachusetts.
57 DeFlavio JR, Rolin SA, Nordstrom BR, Kazal LA. (2015). Analysis of barriers to adoption of buprenorphine maintenance therapy by family physicians. Rural Remote Health.
58 Quest TL, Merrill JO, Roll J, Saxon AJ, Rosenblatt RA. (2012). Buprenorphine therapy for opioid addiction in rural Washington: The experience of the early adopters. Journal of Opioid Management.
59 Hawk KF, Vaca FE, D'Onofrio G. (2015). Reducing fatal opioid overdose: Prevention, treatment and harm reduction strategies. The Yale Journal of Biology and Medicine.
60 Ritter A, Cameron J. (2006). A review of the efficacy and effectiveness of harm reduction strategies for alcohol, tobacco and illicit drugs. Drug and Alcohol Review.
61 Hunt N, Ashton M, Lenton S, Mitcheson L, Nelles B, Stimson G. (2003). A review of the evidence-base for harm reduction approaches to drug use.
62 Wheeler E, Davidson PJ, Jones TS, Irwin KS. (2012). Community-based opioid overdose prevention programs providing naloxone—United States, 2010. MMWR.
63 Marlatt GA, Larimer ME, Witkiewitz K. (2011). Harm reduction: Pragmatic strategies for managing high-risk behaviors.
64 Gottheil E, Sterling RC, Weinstein SP. (1997). Outreach engagement efforts: Are they worth the effort?. The American Journal of Drug and Alcohol Abuse.
65 Center for Substance Abuse Treatment. (2009). Substance abuse treatment: Addressing the specific needs of women.
66 Reback CJ, Fletcher JB. (2014). HIV prevalence, substance use, and sexual risk behaviors among transgender women recruited through outreach. AIDS and Behavior.
67 Carmona J, Slesnick N, Guo X, Murnan A, Brakenhoff B. (2015). Predictors of outreach meetings among substance using homeless youth. Community Mental Health Journal.
68 Tobias C, Cunningham WE, Cunningham CO, Pounds MB. (2007). Making the connection: The importance of engagement and retention in HIV medical care. AIDS Patient Care and STDs.
69 Fisk D, Rakfeldt J, McCormack E. (2006). Assertive outreach: An effective strategy for engaging homeless persons with substance use disorders into treatment. The American Journal of Drug and Alcohol Abuse.
70 Bowman S, Engelman A, Koziol J, Mahoney L, Maxwell C, Mckenzie M. (2014). The Rhode Island community responds to opioid overdose deaths. Rhode Island Medical Journal.
71 Substance Abuse and Mental Health Administration. National Recovery Month.
72 National Safety Council. (2015). Prescription drug community action kit: Public education and media.
73 Centers for Disease Control and Prevention. (2015). HIV and injection drug use in the United States.
74 Centers for Disease Control and Prevention. (2014). HIV surveillance report, 2014.
75 Centers for Disease Control and Prevention. (2016). Surveillance for viral hepatitis – United States, 2014.
76 Ingram M. (2014). The impact of syringe and needle exchange programs on drug use rates in the United States. Master's thesis.
77 Rich JD, Adashi EY. (2015). Ideological anachronism involving needle and syringe exchange programs: Lessons from the Indiana HIV outbreak. JAMA.
78 Aspinall EJ, Nambiar D, Goldberg DJ, Hickman M, Weir A, Van Velzen E, Hutchinson SJ. (2014). Are needle and syringe programmes associated with a reduction in HIV transmission among people who inject drugs: A systematic review and meta-analysis. International Journal of Epidemiology.
79 Palmateer N, Kimber J, Hickman M, Hutchinson S, Rhodes T, Goldberg D. (2010). Evidence for the effectiveness of sterile injecting equipment provision in preventing hepatitis C and human immunodeficiency virus transmission among injecting drug users: A review of reviews. Addiction.
80 National Institute on Drug Abuse. (2015). Overdose death rates.
81 Cowan K. (2016). CVS pharmacies in NY to sell naloxone without prescription.
82 StopOverdose.org. Naloxone (Narcan®): Frequently asked questions.
83 European Monitoring Centre for Drugs and Drug Addiction. (2015). Preventing fatal overdoses: A systematic review of the effectiveness of take-home naloxone.
84 Walley AY, Xuan Z, Hackman HH, Quinn E, Doe-Simkins M, Sorensen-Alawad A, Ozonoff A. (2013). Opioid overdose rates and implementation of overdose education and nasal naloxone distribution in Massachusetts: Interrupted time series analysis. BMJ.
85 National Institute on Drug Abuse. (2012). Principles of drug addiction treatment: A research-based guide.
86 Kim D, Irwin KS, Khoshnood K. (2009). Expanded access to naloxone: Options for critical response to the epidemic of opioid overdose mortality. The American Journal of Public Health.
87 American Society of Addiction Medicine. (2014). The ASAM standards of care for the addiction specialist physician.
88 Mark TL, Dilonardo JD, Chalk M, Coffey RM. (2002). Trends in inpatient detoxification services, 1992-1997. Journal of Substance Abuse Treatment.
89 Mark TL, Vandivort-Warren R, Montejano LB. (2006). Factors affecting detoxification readmission: Analysis of public sector data from three states. Journal of Substance Abuse Treatment.
90 Lee MT, Horgan CM, Garnick DW, Acevedo A, Panas L, Ritter GA, Reynolds M. (2014). A performance measure for continuity of care after detoxification: Relationship with outcomes. Journal of Substance Abuse Treatment.
91 Millette S. (2013). Treatment for substance use disorders – The continuum of care. National Partnership on Alcohol Misuse and Crime.
92 National Institute on Drug Abuse. (2014). Principles of adolescent substance use disorder treatment: A research-based guide.
93 Gastfriend DR, Mee-Lee D. (2004). The ASAM patient placement criteria: Context, concepts and continuing development. Journal of Addictive Diseases.
94 Stallvik M, Gastfriend DR, Nordahl HM. (2015). Matching patients with substance use disorder to optimal level of care with the ASAM criteria software. Journal of Substance Use.
95 The American Society of Addiction Medicine (ASAM). Continuum: The ASAM criteria decision engine.
96 Substance Abuse and Mental Health Services Administration. (2014). Trauma-informed care in behavioral health services.
97 American Psychiatric Association. (2013). Diagnostic and statistical manual of mental disorders (DSM-5).
98 McLellan AT, Luborsky L, O'Brien CP, Woody GE. An improved diagnostic instrument for substance abuse patients: The Addiction Severity Index. Journal of Nervous & Mental Diseases.
99 Cottler LB. (2000). Composite international diagnostic interview—Substance Abuse Module (SAM).
100 Hasin D, Samet S. Psychiatric Research Interview for Substance and Mental Disorders (PRISM).
101 Kelly TM, Daley DC, Douaihy AB. (2012). Treatment of substance abusing patients with comorbid psychiatric disorders. Addictive Behaviors.
102 Center for Substance Abuse Treatment. (2006). Chapter 10. Addressing diverse populations in intensive outpatient treatment. Clinical issues in intensive outpatient treatment.
103 Prendergast ML, Messina NP, Hall EA, Warda US. (2011). The relative effectiveness of women-only and mixed-gender treatment for substance-abusing women. Journal of Substance Abuse Treatment.
104 Messina N, Grella CE, Cartier J, Torres S. (2010). A randomized experimental study of gender-responsive substance abuse treatment for women in prison. Journal of Substance Abuse Treatment.
105 Wisdom JP, Pollock MN, Hopping-Winn A. (2011). Service engagement and retention for women with substance use disorders.
106 Sheedy CK, Whitter M. (2009). Guiding principles and elements of recovery-oriented systems of care: What do we know from the research?.
107 Greenfield SF, Grella CE. (2009). What is “women-focused” treatment for substance use disorders?. Psychiatric Services.
108 Coyhis D, Simonelli R. (2008). The Native American healing experience. Substance Use & Misuse.
109 Guerrero EG, Marsh JC, Duan L, Oh C, Perron B, Lee B. (2013). Disparities in completion of substance abuse treatment between and within racial and ethnic groups. Health Services Research.
110 Guerrero EG, Marsh JC, Khachikian T, Amaro H, Vega WA. (2013). Disparities in Latino substance use, service use, and treatment: Implications for culturally and evidence-based interventions under health care reform. Drug and Alcohol Dependence.
111 Jones JH, Treiber LA, Jones MC. (2014). Intervening at the intersection of medication adherence and health literacy. The Journal for Nurse Practitioners.
112 Alegría M, Alvarez K, Ishikawa RZ, DiMarzio K, McPeck S. (2016). Removing obstacles to eliminating racial and ethnic disparities in behavioral health care. Health Affairs.
113 Senreich E. (2010). Are specialized LGBT program components helpful for gay and bisexual men in substance abuse treatment?. Substance Use & Misuse.
114 Saloner B, Le Cook B. (2013). Blacks and Hispanics are less likely than whites to complete addiction treatment, largely due to socioeconomic factors. Health Affairs.
115 Substance Abuse and Mental Health Services Administration. (2013). Disaster planning handbook for behavioral health treatment programs. Technical Assistance Publication (TAP) Series, No. 34.
116 National Institute on Drug Abuse. (2016). DrugFacts: Treatment approaches for drug addiction.
117 Kleber HD, Weiss RD, Anton RF, George TP, Greenfield SF, Kosten TR, Smith Connery H. (2006). Practice guideline for the treatment of patients with substance use disorders.
118 Food and Drug Administration. (2015). Suboxone®: Highlights of prescribing information.
119 Substance Abuse and Mental Health Services Administration. (2015). Federal Guidelines for Opioid Treatment Programs.
120 Lee J, Kresina TF, Campopiano M, Lubran R, Clark HW. (2015). Use of pharmacotherapies in the treatment of alcohol use disorders and opioid dependence in primary care. BioMed Research International, 2015.
121 Bonhomme J, Shim RS, Gooden R, Tyus D, Rust G. (2012). Opioid addiction and abuse in primary care practice: a comparison of methadone and buprenorphine as treatment options. Journal of the National Medical Association.
122 Kresina TF, Melinda C, Lee J, Ahadpour M, Robert L. (2015). Reducing mortality of people who use opioids through medication assisted treatment for opioid dependence. Journal of HIV & Retro Virus.
123 Schwartz RP, Gryczynski J, O'Grady KE, Sharfstein JM, Warren G, Olsen Y, Jaffe JH. (2013). Opioid agonist treatments and heroin overdose deaths in Baltimore, Maryland, 1995-2009. American Journal of Public Health.
124 Mattick RP, Breen C, Kimber J, Davoli M. (2014). Buprenorphine maintenance versus placebo or methadone maintenance for opioid dependence. Cochrane Database of Systematic Reviews.
125 National Consensus Development Panel on Effective Medical Treatment of Opiate Addiction. (1998). Effective medical treatment of opiate addiction. JAMA.
126 Joseph H, Stancliff S, Langrod J. (2000). Methadone maintenance treatment (MMT): A review of historical and clinical issues. Mount Sinai Journal of Medicine.
127 Kreek MJ, Borg L, Ducat E, Ray B. (2010). Pharmacotherapy in the treatment of addiction: Methadone. Journal of Addictive Diseases.
128 Perkins ME, Bloch HI. (1970). Survey of a methadone maintenance treatment program. American Journal of Psychiatry.
129 Fiellin DA, Friedland GH, Gourevitch MN. (2006). Opioid dependence: Rationale for and efficacy of existing and new treatments. Clinical Infectious Diseases.
130 Anderson IB, Kearney TE. (2000). Use of methadone. Western Journal of Medicine.
131 Säwe J, Hansen J, Ginman C, Hartvig P, Jakobsson P, Nilsson M, Anggård E. (1981). Patient-controlled dose regimen of methadone for chronic cancer pain. BMJ.
132 Sees KL, Delucchi KL, Masson C, Rosen A, Clark HW, Robillard H, Hall SM. (2000). Methadone maintenance vs 180-day psychosocially enriched detoxification for treatment of opioid dependence: A randomized controlled trial. JAMA.
133 Fullerton CA, Kim M, Thomas CP, Lyman DR, Montejano LB, Dougherty RH, Delphin-Rittmon ME. (2014). Medication-assisted treatment with methadone: Assessing the evidence. Psychiatric Services.
134 Connock M, Juarez-Garcia A, Jowett S, Frew E, Liu Z, Taylor RJ, Taylor RS. (2007). Methadone and buprenorphine for the management of opioid dependence: A systematic review and economic evaluation. Health Technology Assessment.
135 Stotts AL, Dodrill CL, Kosten TR. (2009). Opioid dependence treatment: Options in pharmacotherapy. Expert Opinion on Pharmacotherapy.
136 Substance Abuse and Mental Health Services Administration. (2014). National Survey of Substance Abuse Treatment Services (N-SSATS): 2013 Data on substance abuse treatment facilities.
137 Stancliff S, Joseph H, Fong C, Furst T, Comer SD, Roux P. (2012). Opioid maintenance treatment as a harm reduction tool for opioid-dependent individuals in New York City: The need to expand access to buprenorphine/naloxone in marginalized populations. Journal of Addictive Diseases.
138 Volkow ND, Frieden TR, Hyde PS, Cha SS. (2014). Medication-assisted therapies—tackling the opioid-overdose epidemic. New England Journal of Medicine.
139 Center for Substance Abuse Treatment. (2005). Medication-assisted treatment for opioid addiction in opioid treatment programs.
140 Thomas CP, Fullerton CA, Kim M, Montejano L, Lyman DR, Dougherty RH, Delphin-Rittmon ME. (2014). Medication-assisted treatment with buprenorphine: Assessing the evidence. Psychiatric Services.
141 Pathan H, Williams J. (2012). Basic opioid pharmacology: An update. British Journal of Pain.
142 Schuman-Olivier Z, Albanese M, Nelson SE, Roland L, Puopolo F, Klinker L, Shaffer HJ. (2010). Self-treatment: Illicit buprenorphine use by opioid-dependent treatment seekers. Journal of Substance Abuse Treatment.
143 Cicero TJ, Ellis MS, Surratt HL, Kurtz SP. (2014). Factors contributing to the rise of buprenorphine misuse: 2008 - 2013. Drug and Alcohol Dependence.
144 Monico LB, Mitchell SG, Gryczynski J, Schwartz RP, O'Grady KE, Olsen YK, Jaffe JH. (2015). Prior experience with non-prescribed buprenorphine: Role in treatment entry and retention. Journal of Substance Abuse Treatment.
145 Jacobs P, Ang A, Hillhouse MP, Saxon AJ, Nielsen S, Wakim PG, Blaine JD. (2015). Treatment outcomes in opioid dependent patients with different buprenorphine/naloxone induction dosing patterns and trajectories. The American Journal on Addictions.
146 Center for Substance Abuse Treatment. (2004). Clinical guidelines for the use of buprenorphine in the treatment of opioid addiction.
147 (2016). Medication assisted treatment for opioid use disorders. Fed. Reg.
148 The Henry J. Kaiser Family Foundation. (2015). Primary care physicians by field.
149 Stein BD, Pacula RL, Gordon AJ, Burns RM, Leslie DL, Sorbero MJ, Dick AW. (2015). Where is buprenorphine dispensed to treat opioid use disorders? The role of private offices, opioid treatment programs, and substance abuse treatment facilities in urban and rural counties. Milbank Quarterly.
150 Sigmon SC. (2015). The untapped potential of office-based buprenorphine treatment. JAMA Psychiatry.
151 Substance Abuse and Mental Health Services Administration. (2009). The facts about naltrexone for treatment of opioid addiction.
152 Substance Abuse and Mental Health Services Administration. (2012). An introduction to extended-release injectable naltrexone for the treatment of people with opioid dependence. SAMHSA Advisory.
153 Substance Abuse and Mental Health Services Administration. (2015). Clinical use of extended-release injectable naltrexone in the treatment of opioid use disorder: A brief guide.
154 Miller PM, Book SW, Stewart SH. (2011). Medical treatment of alcohol dependence: A systematic review. The International Journal of Psychiatry in Medicine.
155 National Institute on Alcohol Abuse and Alcoholism. (2005). Helping patients who drink too much: A clinician's guide.
156 Substance Abuse and Mental Health Services Administration & National Institute on Alcohol Abuse and Alcoholism. (2015). Medication for the treatment of alcohol use disorder: A brief guide.
157 Lin SK. (2014). Pharmacological means of reducing human drug dependence: A selective and narrative review of the clinical literature. The British Journal of Clinical Pharmacology.
158 National Council on Alcoholism and Drug Dependence. NCADD's consumer guide to medication-assisted recovery.
159 Kufahl PR, Watterson LR, Olive MF. (2014). The development of acamprosate as a treatment against alcohol relapse. Expert Opinion on Drug Discovery.
160 Zindel LR, Kranzler HR. (2014). Pharmacotherapy of alcohol use disorders: Seventy-five years of progress. Journal of Studies on Alcohol and Drugs.
161 Chick J, Gough K, Falkowski W, Kershaw P, Hore B, Mehta B, Torley D. (1992). Disulfiram treatment of alcoholism. The British Journal of Psychiatry.
162 Vuittonet CL, Halse M, Leggio L, Fricchione SB, Brickley M, Haass-Koffler CL, Kenna GA. (2014). Pharmacotherapy for alcoholic patients with alcoholic liver disease. American Journal of Health-System Pharmacy.
163 alcoholrehab.com. Naltrexone and alcohol rehab.
164 Mannelli P, Peindl K, Masand PS, Patkar AA. (2007). Long-acting injectable naltrexone for the treatment of alcohol dependence. Expert Review of Neurotherapeutics.
165 Rösner S, Hackl-Herrwerth A, Leucht S, Lehert P, Vecchi S, Soyka M. (2010). Acamprosate for alcohol dependence. The Cochrane Database of Systematic Reviews.
166 Jonas DE, Amick HR, Feltner C, et al., Bobashev G, Thomas K, Garbutt JC. (2014). Pharmacotherapy for adults with alcohol use disorders in outpatient settings: A systematic review and meta-analysis. JAMA.
167 Maisel NC, Blodgett JC, Wilbourne PL, Humphreys K, Finney JW. (2013). Meta-analysis of naltrexone and acamprosate for treating alcohol use disorders: When are these medications most helpful?. Addiction.
168 Substance Abuse and Mental Health Services Administration. (2013). Report to Congress on the nation's substance abuse and mental health workforce issues.
169 McGovern MP. (2003). Evidence-based practices for substance use disorders. Psychiatric Clinics of North America.
170 Center for Substance Abuse Treatment. (2005). Substance abuse treatment: Group therapy.
171 Wandersman A, Imm P, Chinman M, Kaftarian S. (2000). Getting to outcomes: A results-based approach to accountability. Evaluation and Program Planning.
172 Morgenstern J, Blanchard KA, Morgan TJ, Labouvie E, Hayaki J. (2001). Testing the effectiveness of cognitive-behavioral treatment for substance abuse in a community setting: Within treatment and posttreatment findings. Journal of Consulting and Clinical Psychology.
173 Carroll KM, Onken LS. (2005). Behavioral therapies for drug abuse. Journal of the American Psychiatric Association.
174 McHugh RK, Hearon BA, Otto MW. (2010). Cognitive-behavioral therapy for substance use disorders. Psychiatric Clinics of North America.
175 Gregory VL. (2011). Cognitive-behavioral therapy for comorbid bipolar and substance use disorders: A systematic review of controlled trials. Mental Health and Substance Use.
176 Quello SB, Brady KT, Sonne SC. (2005). Mood disorders and substance use disorder: A complex comorbidity. Science & Practice Perspectives.
177 Higgins ST, Heil SH, Sigmon SC. (2013). Voucher-based contingency management in the treatment of substance use disorders. Madden GJ, Dube WV, Hackenberg TD, Hanley GP, Lattal KA, editors. APA handbook of behavior analysis, Vol. 2: Translating principles into practice.
178 Carroll KM, Nich C, Petry NM, Eagan DA, Shi JM, Ball SA. (2016). A randomized factorial trial of disulfiram and contingency management to enhance cognitive behavioral therapy for cocaine dependence. Drug and Alcohol Dependence.
179 Carroll KM, Easton CJ, Nich C, Hunkele KA, Neavins TM, Sinha R, Rounsaville BJ. (2006). The use of contingency management and motivational/skills-building therapy to treat young adults with marijuana dependence. Journal of Consulting and Clinical Psychology.
180 Secades-Villa R, Garcia-Rodriguez O, Garcia-Fernandez G, Sanchez-Hervas E, Fernandez-Hermida JR, Higgins ST. (2011). Community reinforcement approach plus vouchers among cocaine-dependent outpatients: Twelve-month outcomes. Psychology of Addictive Behaviors.
181 Dennis M, Godley SH, Diamond G, Tims FM, Babor T, Donaldson J, Webb C. (2004). The Cannabis Youth Treatment (CYT) Study: Main findings from two randomized trials. Journal of Substance Abuse Treatment.
182 Slesnick N, Prestopnik JL, Meyers RJ, Glassman M. (2007). Treatment outcome for street-living, homeless youth. Addictive Behaviors.
183 Burlew AK, Montgomery L, Kosinski AS, Forcehimes AA. (2013). Does treatment readiness enhance the response of African American substance users to motivational enhancement therapy?. Psychology of Addictive Behaviors.
184 Miles LA. (2015). Motivational enhancement therapy: Treatment for substance abuse & more.
185 Tevyaw TOL, Monti PM. (2004). Motivational enhancement and other brief interventions for adolescent substance abuse: Foundations, applications and evaluations. Addiction.
186 Helstrom A, Hutchison K, Bryan A. (2007). Motivational enhancement therapy for high-risk adolescent smokers. Addictive Behaviors.
187 Rawson RA, Gonzales R, Pearce V, Ang A, Marinelli-Casey P, Brummer J. (2008). Methamphetamine dependence and HIV risk behavior. Journal of Substance Abuse Treatment.
188 Shoptaw S, Reback CJ. (2007). Methamphetamine use and infectious disease-related behaviors in men who have sex with men: Implications for interventions. Addiction.
189 Substance Abuse and Mental Health Services Administration. (2012). Using matrix with women clients: A supplement to the matrix intensive outpatient treatment for people with stimulant use disorders.
190 Walitzer KS, Dermen KH, Barrick C. (2009). Facilitating involvement in Alcoholics Anonymous during out-patient treatment: A randomized clinical trial. Addiction.
191 Kaskutas LA, Subbaraman MS, Witbrodt J, Zemore SE. (2009). Effectiveness of making Alcoholics Anonymous easier: A group format 12-step facilitation approach. Journal of Substance Abuse Treatment.
192 Crits-Christoph P, Siqueland L, Blaine J, Frank A, Luborsky L, Onken LS, Beck AT. (1999). Psychosocial treatments for cocaine dependence: National Institute on Drug Abuse Collaborative Cocaine Treatment Study. Archives of General Psychiatry.
193 Allen JP, Mattson ME, Miller WR, Tonigan JS, Connors GJ, Rychtarik RG, Litt M. (1997). Matching alcoholism treatments to client heterogeneity: Project MATCH posttreatment drinking outcomes. Journal of Studies on Alcohol.
194 Litt MD, Kadden RM, Kabela-Cormier E, Petry NM. (2009). Changing network support for drinking: Network support project 2-year follow-up. Journal of Consulting and Clinical Psychology.
195 Timko C, DeBenedetti A. (2007). A randomized controlled trial of intensive referral to 12-step self-help groups: One-year outcomes. Drug and Alcohol Dependence.
196 Longabaugh R, Wirtz PW, Zweben A, Stout RL. (1998). Network support for drinking, Alcoholics Anonymous and long-term matching effects. Addiction.
197 Thevos AK, Thomas SE, Randall CL. (2001). Social support in alcohol dependence and social phobia: Treatment comparisons. Research on Social Work Practice.
198 Cooney NL, Babor TF, DiClemente CC, Del Boca FK. (2003). Clinical and scientific implications of Project MATCH. Babor TF, Boca FKD, editors. Treatment Matching in Alcoholism.
199 Donovan DM, Daley DC, Brigham GS, Hodgkins CC, Perl HI, Garrett S, Zammarelli L. (2013). Stimulant abuser groups to engage in 12-step (STAGE-12): A multisite trial in the NIDA clinical trials network. Journal of Substance Abuse Treatment.
200 Yalom ID, Leszcz M. (2005). Theory and practice of group psychotherapy.
201 Humphreys K. (2004). Tale telling in an alcohol mutual help organization. New Directions in Alcohol Studies.
202 Labbe AK, Slaymaker V, Kelly JF. (2014). Toward enhancing 12-step facilitation among young people: A systematic qualitative investigation of young adults' 12-step experiences. Substance Abuse.
203 Kelly JF, Magill M, Stout RL. (2009). How do people recover from alcohol dependence? A systematic review of the research on mechanisms of behavior change in Alcoholics Anonymous. Addiction Research & Theory.
204 White WL, Kelly JF, Roth JD. (2012). New addiction-recovery support institutions: Mobilizing support beyond professional addiction treatment and recovery mutual aid. Journal of Groups in Addiction & Recovery.
205 Hester RK, Lenberg KL, Campbell W, Delaney HD. (2013). Overcoming addictions, a web-based application, and SMART recovery, an online and in-person mutual help group for problem drinkers, Part 1: Three-month outcomes of a randomized controlled trial. Journal of Medical Internet Research.
206 Norris SL, Nichols PJ, Caspersen CJ, Glasgow RE, Engelgau MM, Jack L, McCulloch D. (2002). Increasing diabetes self-management education in community settings: A systematic review. American Journal of Preventive Medicine.
207 Donohue B, Azrin N, Allen DN, Romero V, Hill HH, Tracy K, Van Hasselt VB. (2009). Family behavior therapy for substance abuse and other associated problems: A review of its intervention components and applicability. Behavior Modification.
208 Winters J, Fals-Stewart W, O'Farrell TJ, Birchler GR, Kelley ML. (2002). Behavioral couples therapy for female substance-abusing patients: Effects on substance use and relationship adjustment. Journal of Consulting and Clinical Psychology.
209 Stanton D, Heath A. (2004). Family/couples approaches to treatment engagement and therapy. Lowinson JH, Ruiz P, editors. Substance abuse: A comprehensive textbook.
210 O'Farrell TJ, Clements K. (2012). Review of outcome research on marital and family therapy in treatment for alcoholism. Journal of Marital & Family Therapy.
211 Center for Behavioral Health Statistics and Quality. (2013). The NSDUH Report: Adults with mental illness or substance use disorder account for 40 percent of all cigarettes smoked.
212 Baca CT, Yahne CE. (2009). Smoking cessation during substance abuse treatment: What you need to know. Journal of Substance Abuse Treatment.
213 Prochaska JJ, Delucchi K, Hall SM. (2004). A meta-analysis of smoking cessation interventions with individuals in substance abuse treatment or recovery. Journal of Consulting and Clinical Psychology.
214 Substance Abuse and Mental Health Administration. (2015). Recovery and recovery support.
215 Ruiz BS, Korchmaros JD, Greene A, Hedges K. (2011). Evidence-based substance abuse treatment for adolescents: Engagement and outcomes. Practice: Social Work in Action.
216 National Council for Community Behavioral Healthcare. (2012). HIT adoption and readiness for meaningful use in community behavioral health: Report on the 2012 National Council Survey.
217 Health Resources and Services Administration. What is telehealth?.
218 Kiluk BD, Carroll KM. (2013). New developments in behavioral treatments for substance use disorders. Current Psychiatry Reports.
219 Olmstead TA, Ostrow CD, Carroll KM. (2010). Cost-effectiveness of computer-assisted training in cognitive-behavioral therapy as an adjunct to standard care for addiction. Drug and Alcohol Dependence.
220 Marsch LA, Dallery J. (2012). Advances in the psychosocial treatment of addiction: The role of technology in the delivery of evidence-based psychosocial treatment. The Psychiatric Clinics of North America.
221 Rosa C, Campbell ANC, Miele GM, Brunner M, Winstanley EL. (2015). Using e-technologies in clinical trials. Contemporary Clinical Trials.
222 Johnson K, Isham A, Shah DV, Gustafson DH. (2011). Potential roles for new communication technologies in treatment of addiction. Current Psychiatry Reports.
223 Anderson M. (2015). Technology device ownership: 2015.
224 Anderson M, Perrin A. (2015). 15% of Americans don't use the internet. Who are they?.
225 Kiluk BD, Sugarman DE, Nich C, Gibbons CJ, Martino S, Rounsaville BJ, Carroll KM. (2011). A methodological analysis of randomized clinical trials of computer-assisted therapies for psychiatric disorders: Toward improved standards for an emerging field. American Journal of Psychiatry.
226 Marsch LA, Guarino H, Acosta M, Aponte-Melendez Y, Cleland C, Grabinski M, Edwards J. (2014). Web-based behavioral treatment for substance use disorders as a partial replacement of standard methadone maintenance treatment. Journal of Substance Abuse Treatment.
227 King VL, Brooner RK, Peirce JM, Kolodner K, Kidorf MS. (2014). A randomized trial of Web-based videoconferencing for substance abuse counseling. Journal of Substance Abuse Treatment.
228 Gustafson DH, McTavish FM, Chih MY, Atwood AK, Johnson RA, Boyle MG, Shah D. (2014). A smartphone application to support recovery from alcoholism: A randomized clinical trial. JAMA Psychiatry.
229 Carroll KM, Kiluk BD, Nich C, Gordon MA, Portnoy GA, Marino DR, Ball SA. (2014). Computer-assisted delivery of cognitive-behavioral therapy: Eficacy and durability of CBT4CBT among cocaine-dependent individuals maintained on methadone. American Journal of Psychiatry.
230 Hasin DS, Aharonovich E, O'Leary A, Greenstein E, Pavlicova M, Arunajadai S, Johnston B. (2013). Reducing heavy drinking in HIV primary care: A randomized trial of brief intervention, with and without technological enhancement. Addiction.
231 Rooke S, Copeland J, Norberg M, Hine D, McCambridge J. (2013). Effectiveness of a self-guided web-based cannabis treatment program: Randomized controlled trial. Journal of Medical Internet Research.
232 Kay-Lambkin FJ, Baker AL, Kelly B, Lewin TJ. (2011). Clinician-assisted computerised versus therapist-delivered treatment for depressive and addictive disorders: A randomised controlled trial. Medical Journal of Australia.
233 Campbell AN, Nunes EV, Matthews AG, Stitzer M, Miele GM, Polsky D, Ghitza UE. (2014). Internet-delivered treatment for substance abuse: A multisite randomized controlled trial. Journal of the American Psychiatric Association.
234 Cunningham JA, Wild TC, Cordingley J, Van Mierlo T, Humphreys K. (2009). A randomized controlled trial of an internet-based intervention for alcohol abusers. Addiction.
235 Kypri K, McCambridge J, Vater T, Bowe SJ, Saunders JB, Cunningham JA, Horton NJ. (2013). Web-based alcohol intervention for Mäori university students: Double-blind, multi-site randomized controlled trial. Addiction.
236 Hester RK, Delaney HD, Campbell W. (2012). The college drinker's check-up: Outcomes of two randomized clinical trials of a computer-delivered intervention. Psychology of Addictive Behaviors.
237 Walters ST, Vader AM, Harris TR. (2007). A controlled trial of web-based feedback for heavy drinking college students. Prevention Science.
238 Palfai T, Tahaney K, Winter M, Saitz R. (2016). Readiness-to-change as a moderator of a web-based brief intervention for marijuana among students identified by health center screening. Drug and Alcohol Dependence.
239 Hankin A, Haley L, Baugher A, Colbert K, Houry D. (2015). Kiosk versus in-person screening for alcohol and drug use in the emergency department: patient preferences and disclosure. Western Journal of Emergency Medicine.
240 Mello MJ, Longabaugh R, Baird J, Nirenberg T, Woolard R. (2008). DIAL: A telephone brief intervention for high-risk alcohol use with injured emergency department patients. Annals of Emergency Medicine.
241 McKay JR, Lynch KG, Shepard DS, Pettinati HM. (2005). The effectiveness of telephone-based continuing care for alcohol and cocaine dependence: 24-month outcomes. Archives of General Psychiatry.
242 Bewick BM, Trusler K, Barkham M, Hill AJ, Cahill J, Mulhern B. (2008). The effectiveness of web-based interventions designed to decrease alcohol consumption—A systematic review. Preventive Medicine.
243 Carey KB, Scott-Sheldon LA, Elliott JC, Bolles JR, Carey MP. (2009). Computer-delivered interventions to reduce college student drinking: A meta-analysis. Addiction.
244 Elliott JC, Carey KB, Bolles JR. (2008). Computer-based interventions for college drinking: A qualitative review. Addictive Behaviors.
245 Kypri K, Saunders JB, Williams SM, McGee RO, Langley JD, Cashell-Smith ML, Gallagher SJ. (2004). Web-based screening and brief intervention for hazardous drinking: A double-blind randomized controlled trial. Addiction.
246 Neumann T, Neuner B, Weiss-Gerlach E, Tonnesen H, Gentilello LM, Wernecke KD, Spies CD. (2006). The effect of computerized tailored brief advice on at-risk drinking in subcritically injured trauma patients. Journal of Trauma and Acute Care Surgery.
247 Community Preventive Services Task Force. (2012). Preventing excessive alcohol consumption: Electronic screening and brief interventions (e-SBI).
248 Riper H, Kramer J, Conijn B, Smit F, Schippers G, Cuijpers P. (2009). Translating effective web-based self-help for problem drinking into the real world. Alcoholism: Clinical and Experimental Research.
249 Brief DJ, Rubin A, Keane TM, Enggasser JL, Roy M, Helmuth E, Rosenbloom D. (2013). Web intervention for OEF/OIF veterans with problem drinking and PTSD symptoms: A randomized clinical trial. Journal of Consulting and Clinical Psychology.
250 Litvin EB, Abrantes AM, Brown RA. (2013). Computer and mobile technology-based interventions for substance use disorders: An organizing framework. Addictive Behaviors.
251 Moore BA, Fazzino T, Garnet B, Cutter CJ, Barry DT. (2011). Computer-based interventions for drug use disorders: A systematic review. Journal of Substance Abuse Treatment.
252 Kiluk BD, Nich C, Babuscio T, Carroll KM. (2010). Quality vs. quantity: Acquisition of coping skills following computerized cognitive behavioral therapy for substance use disorders. Addiction.
253 Klein AA, Slaymaker VJ, Dugosh KL, McKay JR. (2012). Computerized continuing care support for alcohol and drug dependence: A preliminary analysis of usage and outcomes. Journal of Substance Abuse Treatment.
254 Davis TA, Ancis J. (2012). Look to the relationship: A review of African American women substance users' poor treatment retention and working alliance development. Substance Use & Misuse.
255 Substance Abuse and Mental Health Services Administration & Center for Behavioral Health Statistics and Quality. (2012). The NSDUH Report: Need for and receipt of substance use treatment among Hispanics.
256 Substance Abuse and Mental Health Services Administration & Center for Behavioral Health Statistics and Quality. (2013). Need for and receipt of substance use treatment among Blacks.
257 Longshore D, Grills C. (2000). Motivating illegal drug use recovery: Evidence for a culturally congruent intervention. Journal of Black Psychology.
258 Gil AG, Wagner EF, Tubman JG. (2004). Culturally sensitive substance abuse intervention for Hispanic and African American adolescents: Empirical examples from the Alcohol Treatment Targeting Adolescents in Need (ATTAIN) project. Addiction.
259 Milligan CO, Nich C, Carroll KM. (2004). Ethnic differences in substance abuse treatment retention, compliance, and outcome from two clinical trials. Psychiatric Services.
260 Tonigan JS. (2003). Project Match treatment participation and outcome by self-reported ethnicity. Alcoholism: Clinical & Experimental Research.
261 Witkiewitz K, Bowen S, Douglas H, Hsu SH. (2013). Mindfulness-based relapse prevention for substance craving. Addictive Behaviors.
262 Beckstead DJ, Lambert MJ, DuBose AP, Linehan M. (2015). Dialectical behavior therapy with American Indian/Alaska Native adolescents diagnosed with substance use disorders: Combining an evidence based treatment with cultural, traditional, and spiritual beliefs. Addictive Behaviors.
263 Niv N, Wong EC, Hser Y-I. (2007). Asian Americans in community-based substance abuse treatment: Service needs, utilization, and outcomes. Journal of Substance Abuse Treatment.
264 Yu J, Warner LA. (2013). Substance abuse treatment readmission patterns of Asian Americans: Comparisons with other ethnic groups. The American Journal of Drug and Alcohol Abuse.
265 Wu L-T, Blazer DG. (2015). Substance use disorders and co-morbidities among Asian Americans and Native Hawaiians/Pacific Islanders. Psychological Medicine.
266 Substance Abuse and Mental Health Services Administration & Center for Behavioral Health Statistics and Quality. (2014). Improving cultural competence.
267 Cochran BN, Cauce AM. (2006). Characteristics of lesbian, gay, bisexual, and transgender individuals entering substance abuse treatment. Journal of Substance Abuse Treatment.
268 McCabe SE, West BT, Hughes TL, Boyd CJ. (2013). Sexual orientation and substance abuse treatment utilization in the United States: Results from a national survey. Journal of Substance Abuse Treatment.
269 Ward BW, Dahlhamer JM, Galinsky AM, Joestl SS. (2014). Sexual orientation and health among US adults: National Health Interview Survey, 2013. National Health Statistics Reports.
270 Marshal MP, Friedman MS, Stall R, King KM, Miles J, Gold MA, Morse JQ. (2008). Sexual orientation and adolescent substance use: A meta-analysis and methodological review. Addiction.
271 Cochran BN, Peavy KM, Robohm JS. (2007). Do specialized services exist for LGBT individuals seeking treatment for substance misuse? A study of available treatment programs. Substance Use & Misuse.
272 Green KE, Feinstein BA. (2012). Substance use in lesbian, gay, and bisexual populations: An update on empirical research and implications for treatment. Psychology of Addictive Behaviors.
273 Lombardi EL, van Servellen G. (2000). Building culturally sensitive substance use prevention and treatment programs for transgendered populations. Journal of Substance Abuse Treatment.
274 Substance Abuse and Mental Health Administration. (2014). Veterans and military families.
275 Hoggatt KJ, Jamison AL, Lehavot K, Cucciare MA, Timko C, Simpson TL. (2015). Alcohol and drug misuse, abuse, and dependence in women veterans. Epidemiologic Reviews.
276 Coker KL, Stefanovics E, Rosenheck R. (2016). Correlates of improvement in substance abuse among dually diagnosed veterans with post-traumatic stress disorder in specialized intensive VA treatment. Psychological Trauma: Theory, Research, Practice, and Policy.
277 Smelson DA, Kline A, Kuhn J, Rodrigues S, O'Connor K, Fisher W, Kane V. (2013). A wraparound treatment engagement intervention for homeless veterans with co-occurring disorders. Psychological Services.
278 The Pew Center on the States. (2008). One in 100: Behind bars in America 2008.
279 Krinsky CS, Lathrop SL, Brown P, Nolte KB. (2009). Drugs, detention, and death: A study of the mortality of recently released prisoners. The American Journal of Forensic Medicine and Pathology.
280 Binswanger IA, Blatchford PJ, Mueller SR, Stern MF. (2013). Mortality after prison release: Opioid overdose and other causes of death, risk factors, and time trends from 1999 to 2009. Annals of Internal Medicine.
281 Møller LF, Matic S, van Den Bergh BJ, Moloney K, Hayton P, Gatherer A. (2010). Acute drug-related mortality of people recently released from prisons. Public Health.
282 Gordon MS, Kinlock TW, Schwartz RP, O'Grady KE. (2008). A randomized clinical trial of methadone maintenance for prisoners: Findings at 6 months post-release. Addiction.
283 Wakeman SE, Rich JD. (2015). Addiction treatment within U.S. Correctional facilities: Bridging the gap between current practice and evidence-based care. Journal of Addictive Diseases.
284 Lee JD, Friedmann PD, Kinlock TW, Nunes EV, Boney TY, Hoskinson RAJ, O'Brien CP. (2016). Extended-release naltrexone to prevent opioid relapse in criminal justice offenders. New England Journal of Medicine.
285 U.S. Department of Justice Office of Justice Programs. (2015). Drug courts.
286 Bhati AS, Roman JK, Chalfin A. (2008). To treat or not to treat: Evidence on the prospects of expanding treatment to drug-involved offenders.
287 Wilson DB, Mitchell O, MacKenzie DL. (2013). Drug courts. Bruinsma G, Weisburd D, editors. Encyclopedia of Criminology and Criminal Justice.
288 Sevigny EL, Fuleihan BK, Ferdik FV. (2013). Do drug courts reduce the use of incarceration? A meta-analysis. Journal of Criminal Justice.
289 Wilson DB, Mitchell O, MacKenzie DL. (2006). A systematic review of drug court effects on recidivism. Journal of Experimental Criminology.
290 Gottfredson DC, Najaka SS, Kearley BW, Rocha CM. (2006). Long-term effects of participation in the Baltimore City drug treatment court: Results from an experimental study. Journal of Experimental Criminology.
291 Belenko S, Patapis P, French MT. (2005). Economic benefits of drug treatment: A critical review of the evidence for policy makers.
292 Mitchell O, Wilson D, Eggers A, MacKenzie D. (2012). Drug courts' effects on criminal offending for juveniles and adults. Campbell Systematic Reviews.
293 Hawken A, Kleiman M. (2009). Managing drug involved probationers with swift and certain sanctions: Evaluating Hawaii's HOPE.
294 Pollack H, Sevigny EL, Reuter P. (2011). If drug treatment works so well, why are so many drug users in prison?. Cook PJ, Ludwig J, McCrary J, editors. Controlling Crime: Strategies and Tradeoffs.
295 Kilmer B, Nicosia N, Heaton P, Midgette G. (2013). Eficacy of frequent monitoring with swift, certain, and modest sanctions for violations: Insights from South Dakota's 24/7 sobriety project. American Journal of Public Health.
296 Midgette G, Kilmer B. (2015). The effect of Montana's 24/7 sobriety program on DUI re-arrest: Insights from a natural experiment with limited administrative data.
297 D'Onofrio G, O'Connor PG, Pantalon MV, Chawarski MC, Busch SH, Owens PH, Fiellin DA. (2015). Emergency department–initiated buprenorphine/naloxone treatment for opioid dependence: A randomized clinical trial. JAMA.
298 Ghitza UE. (2016). Overlapping mechanisms of stress-induced relapse to opioid use disorder and chronic pain: Clinical implications. Frontiers in Psychiatry.
299 Dennis Ml, Titus JC, White MK, Unsicker JI, Hodgkins D. (2003). Global appraisal of individual needs Administration guide for the GAIN and related measures.