# APPENDIX B EVIDENCE-BASED PREVENTION PROGRAMS AND POLICIES

Table B.1 Evidence-Based Interventions for Children Under Age 10

Intervention | Type (Universal, Selective, Indicated) | Domain/Level (Family, School, Community, Multicomponent) | Sample (at pretest)/Ethnicity/Setting Design | Summary Results | Citations: Key Outcome Research/Program Information Source
Nurse-Family Partnership Program (NFP) | Selective | Family | Study 1: N = 300 rural, poor pregnant White women, first births | Study 1: At 13-year follow-up (age 15), parents in the nurse-visits intervention reported their children had fewer behavioral problems due to use of substances (0.15 vs. 0.34), and youth reported fewer days of alcohol consumption in past 6 months (1.09 vs. 2.49). No effects on binge drinking or illicit drug use at age 19. | Olds, et al. (1998)^1^
Nurse-Family Partnership Program (NFP) | Selective | Family | Study 2: N = 743 urban, poor pregnant African American women, first births All studies: RCT/NTC | Study 2: At 10-year follow-up (age 12), lower 30-day use of cigarettes, alcohol, and marijuana (OR = 0.31). | Eckenrode, et al. (2010)^2^ Kitzman, et al. (2010)^3^
Raising Healthy Children (RHC) (Seattle Social Development Project elementary only) | Universal | Family and School | N = 18 urban, multiethnic schools; 810 students in Grades 1-5 QED/NTC RCT/NTC | At 6-year follow-up (age 18), reductions in heavy drinking (15.4% vs. 25.0%); high rates of attrition (quasi-experimental). | Hawkins, et al. (1992)^4^ and (1999)^5^
Raising Healthy Children (RHC) (Seattle Social Development Project elementary only) | Universal | Family and School | N = 18 urban, multiethnic schools; 810 students in Grades 1-5 QED/NTC RCT/NTC | At ages 21, 24, and 27, no significant effects on any form or drug or alcohol use. | Hawkins, et al. (2005)^6^ and (2008)^7^
Raising Healthy Children (RHC) (Seattle Social Development Project elementary only) | Universal | Family and School | N = 18 urban, multiethnic schools; 810 students in Grades 1-5 QED/NTC RCT/NTC | At grades 8-10, reduced growth of frequency of alcohol and marijuana use, no effects on initiation of alcohol, marijuana, and cigarettes(d = .40 for alcohol, d = .57 for marijuana). | Brown, et al. (2005)^8^
Good Behavior Game | Universal | School | N = 864 large urban, multiethnic students in Grades 1-2 RCT/NTC | At ages 19 to 21, intervention males with high aggression in 1st grade (about 25% of boys) had lower rates of alcohol and drug abuse and dependence (65.6% vs. 28.1%). No effect for moderately or low aggressive males and no effect for females. Finding was not replicated in second cohort of the same study. | Kellam, et al. (2008)^9^ and (2014)^10^
Classroom Centered Intervention | Universal | School | N = 9 urban, multiethnic schools; 576 students in Grades1 and 2 RCT/NTC | At 6-year follow-up (Grade 8), reduced risk of starting to use other illegal drugs (heroin, crack, and cocaine powder; 7% vs. 2.6%). | Ialongo, et al. (2001)^11^ Furr-Holden, et al. (2004)^12^
Classroom Centered Intervention | Universal | School | N = 9 urban, multiethnic schools; 576 students in Grades1 and 2 RCT/NTC | No effects on alcohol initiation or marijuana use. | Liu, et al. (2013)^13^
Linking the Interests of Families and Teachers (LIFT) | Universal | Multicomponent | N = 6 schools; 348 primarily White students in Grade 5, college town | At 2- and 3-year follow-up, effects on patterned alcohol use (OR = 1.49) across Grades 6-8. | Eddy, et al. (2003)^14^
Linking the Interests of Families and Teachers (LIFT) | Universal | Multicomponent | RCT/NTC | Lower risk of initiating alcohol use (7% reduction). Also reduced growth of illicit drug use, particularly for females. | DeGarmo, et al. (2009)^15^
Fast Track | Indicated | Multicomponent | N = 4 urban and rural multiethnic communities; 891 children with behavioral problems selected in kindergarten, Grades 1-10 RCT/TAU | No effects on substance use in Grades 9-12. At 10-year follow-up (age 25), decreased probability of DSM alcohol abuse (OR = 0.69), serious substance use (OR = 0.58). Lower drug crime conviction rate (34.7% reduction). No effect on binge drinking or heavy marijuana use. | Dodge, et al. (2015)^16^
Preventive Treatment Program (Montreal) | Selective | Multicomponent | N = 166 urban French Canadian students in Grades 1-2 with early behavioral problems RCT/TAU | At 7-year follow-up, effects on drinking to the point of being drunk at age 15. | Tremblay, et al. (1996)^17^
Preventive Treatment Program (Montreal) | Selective | Multicomponent | N = 166 urban French Canadian students in Grades 1-2 with early behavioral problems RCT/TAU | At 6- to 8- year follow-up, reduction in alcohol use at age 17 (ES = 0.48), and the slope of the number of drugs used between age 14 and 17 (ES = 0.70). | Masse, (1996)^18^

Abbreviations: RCT - Randomized Controlled Trial, QED - Quasi-Experimental Design, TAU - Control Group Received Treatment As Usual, NTC - No Treatment Control, ES - Effect Size, OR - Odds Ratio

Table B.2 Evidence-Based Interventions for Youth Aged 10 to18

Intervention | Type (Universal, Selective, Indicated) | Domain/Level (Family, School, Community, Multicomponent) | Sample (at pretest)/ Ethnicity/ Setting/Design | Summary Results | Citations: Key Outcome Research/Program Information Source
Life Skills Training (LST) | Universal | School | Study 1: N = 56 public schools; 5,954 White, urban students in Grade 7 (1985-1991) | Study 1: 6-year follow-up showed significantly lower incidence of drunkenness (33.5% vs. 40%) but not on rate of monthly, or weekly alcohol use); no effect on marijuana use. 66% reduction in weekly polydrug use (alcohol, marijuana, and tobacco). | Botvin, et al. (1995)^19^
Life Skills Training (LST) | Universal | School | Study 2: N =29 schools in New York; 3,791 urban youth in Grade 7 (high-risk subsample), primarily African American and Hispanic | Study 2:1- and 2-year follow-up showed lower rates of alcohol use, binge drinking, and inhalant use. | Botvin, et al. (2001)^20^ Griffin, et al. (2003)^21^
Life Skills Training (LST) | Universal | School | Study 2a: N = 758 high-risk students from Study 2 | Study 2a: At 1-year follow-up, high-risk participants (21% of sample) reported less drinking (ES = 0.22), inhalant use (ES = 0.14), and polydrug use (ES = 0.21). | Smith, et al. (2004)^22^
Life Skills Training (LST) | Universal | School | Study 3: N = 9 rural public schools; 732 White students in Grade 6 (1999-2002) | Study 3: No significant findings. | Spoth, et al. (2005)^23^
Life Skills Training (LST) | Universal | School | Study 4: N = 36 rural schools; 1,650 primarily White students in Grade 7 (1998-2006) All Studies: RCT/NTC | Study 4: At 1.5-year follow-up, reduction in substance use for females, which became nonsignificant at 2.5-year follow-up. No significant effects for males. At 5.5-year follow-up, lower rate of SU initiation, marijuana initiation (23% reduction), drunkenness (10% reduction), polydrug use, and lifetime methamphetamine use (2.4% vs. 7.6%) when combined with the Strengthening Families Program: For Parents and Youth 10-14. | Spoth, et al. (2008)^25^ and (2006)^24^
School Health and Alcohol Harm Reduction Project (SHAHRP) | Universal | School | N = 14 public secondary schools in metropolitan Perth, Australia; 2,300 students aged 12 to 14 (1997-1999) QED/NTC | At 17-month follow-up (after two years of intervention), reduced weekly drinking (5%) and harm from alcohol use. | McBride, et al. (2000)^26^ and (2004)^27^
Preventure/Adventure | Selective (by Personality Risk) | School | Study 1: N = 13 UK secondary schools; 732 youth aged 13 to 16. Wave 2 youth only (N = 364) | Study 1: At 2-year follow-up, reduced initiation of l cocaine (OR = 0.20) and other drugs (OR = 0.50). No effect on marijuana use. Strongest effects on impulsive subsample. Effects on quantity and binge drinking fade after 6 months. A 24 months, still an effect on problem drinking (ES=0.33; Rutgers Scale). | Conrod, et al. (2010)^28^ and (2011)^29^
Preventure/Adventure | Selective (by Personality Risk) | School | Study 2: N = 21 UK secondary schools; 1,210 high-risk students in Grade 9. Selected as in Study 1, lower risk sample = 1,433 students | Study 2: At 24-month follow-up, high-risk students had lowered quantity of drinking (29% reduction), binge drinking (43% reduction), and problem drinking (29% reduction). Low risk students had lower quantity of drinking (29% reduction) and lower rates of binge drinking (35% reduction). | Conrod, et al. (2013)^30^
Preventure/Adventure | Selective (by Personality Risk) | School | Study 2: N = 21 UK secondary schools; 1,210 high-risk students in Grade 9. Selected as in Study 1, lower risk sample = 1,433 students | At 24-month follow-up, effects on marijuana use fade and are unclear. 24-month effects maintained in the sensation-seeking subsample only (OR = 0.25). | Mahu, et al. (2015)^31^
Preventure/Adventure | Selective (by Personality Risk) | School | Study 3: N = 15 Schools in The Netherlands; 699 high-risk students aged 13 to 15 All Studies: RCT/NTC | Study 3: At 12-month follow-up, effects were ambiguous. Regression models revealed no significant effects on alcohol use, binge drinking, or problem drinking. Latent growth model showed effect on binge drinking. | Lammers, et al. (2015)^32^
Unplugged | Universal | School | N = 170 schools in 7 European countries; 7,079 students aged 12 to 14 | At 18-month follow-up, reductions in any drunkenness (3.8% reduction), frequent drunkenness (2.5% reduction), any cannabis use (2.9% reduction), and frequent cannabis use (2.2% reduction). | Faggiano, et al. (2010)^33^
keepin' It REAL | Universal | School | Study 1:N = 35 public schools in Phoenix, Arizona; 4,235 multiethnic/ urban students in Grade 7 (1998-2000) | Study 1: At 19-month follow-up, lower increases in past-month alcohol and marijuana use for the Mexican American and multicultural version of the program. No effects on the Black/White version. | Hecht, et al. (2003)^34^ and (2006)^35^ Kulis, et al. (2007)^36^
keepin' It REAL | Universal | School | Study 2: N = 30 public schools in Phoenix, Arizona; 3,038 students in Grade 7 (74.3% were Mexican-American) All Studies: RCT/NTC | Study 2: At 1-year follow-up, no significant difference in alcohol or marijuana use. | Marsiglia, et al. (2012)^37^
ATLAS (Athletes Training and Learning to Avoid Steroids) | Universal | School | N = 31 high school football teams from Portland, Oregon; 3,207 athletes (1994-1996) RCT/NTC | At 1-year follow-up, reduced use of alcohol and illicit drug use, and lower rate of drinking and driving. | Goldberg, et al. (2000)^38^
Strengthening Families Program: For Parents and Youth 10-14 | Universal | Family and School/Multicomponent | Study 1:N = 33 Midwestern public schools; 667 primarily White, rural students in Grade 6 | Study 1: At 4-year follow-up, lower lifetime alcohol use (50% vs. 68%), drunkenness (26% vs. 44%), marijuana use (7% vs. 17%), and lower rates of amphetamine use (0% vs. 3.2%). | Spoth, et al. (2001)^39^
Strengthening Families Program: For Parents and Youth 10-14 | Universal | Family and School/Multicomponent | Study 1:N = 33 Midwestern public schools; 667 primarily White, rural students in Grade 6 | At 6-year follow-up, lower rates of substance use initiation (OR = 2.34), lower drunkenness (41% reduction) and lower illicit drug use. | Spoth, et al. (2004)^40^
Strengthening Families Program: For Parents and Youth 10-14 | Universal | Family and School/Multicomponent | Study 1:N = 33 Midwestern public schools; 667 primarily White, rural students in Grade 6 | At age 21, lower rates of substance use initiation (27.5% vs. 28.3%), drunkenness (19% reduction) and illicit drug use (31% reduction). | Spoth, et al. (2009)^41^ and (2012)^42^
Strengthening Families Program: For Parents and Youth 10-14 | Universal | Family and School/Multicomponent | Study 2: N = 36 public schools,1,650 primarily White students in Grade 7 from rural Iowa (1998-2004) All Studies: RCT/NTC | Study 2: At 2.5-year follow-up, shows significantly less alcohol initiation (25.7% vs. 36.7%), marijuana initiation (4.1% vs. 7.9%), and slower growth in weekly drunkenness (39% reduction) when combined with Life Skills Training. | Spoth, et al. (2002)^43^ and (2005)^23^
Strengthening Families Program: For Parents and Youth 10-14 | Universal | Family and School/Multicomponent | Study 2: N = 36 public schools,1,650 primarily White students in Grade 7 from rural Iowa (1998-2004) All Studies: RCT/NTC | At 5.5-year follow-up, lower rate of SU initiation, marijuana initiation (23% reduction), polydrug use, and lifetime methamphetamine use (2.5% vs. 7.6%) when combined with Life Skills Training. | Spoth, et al. (2008)^25^
Strengthening Families Program: For Parents and Youth 10-14 | Universal | Family and School/Multicomponent | Study 2: N = 36 public schools,1,650 primarily White students in Grade 7 from rural Iowa (1998-2004) All Studies: RCT/NTC | At age 25, lower rates of prescription opioid misuse (6.0% vs. 8.8%) and lifetime prescription drug misuse overall (6.3 vs. 9.4) when combined with Life Skills Training. | Spoth, et al. (2013)^44^
Guiding Good Choices | Universal | Family | N =33 rural, Midwestern schools; 883 students in Grade 7 RCT/NTC | Effects on substance use initiation through high school and alcohol-related problems and illicit drug use through early adulthood. No effects on drunkenness. | Spoth, et al. (2009)^41^
Guiding Good Choices | Universal | Family | N =33 rural, Midwestern schools; 883 students in Grade 7 RCT/NTC | At age 22, lower rate of alcohol misuse for women (6% vs. 16%); no effect for men. | Mason, et al (2009)^45^
Strong African American Families | Universal | Family | N = 667 Southern U.S. rural African American students in Grade 7 RCT/NTC | At 2-year follow-up, slower rate of initiation of alcohol (37% vs. 43%). Effect on growth trajectory of alcohol use through 4.5-year follow-up. | Brody, et al. (2006)^46^ and (2010)^47^
SODAS City | Universal | Family | N = 43 community agencies in New York, New Jersey, and Delaware; 514 urban youth (1991-2010) RCT/NTC | At 3-year follow-up, CD-ROM alone and CD-ROM plus parent intervention showed significantly lower past-month alcohol use. | Schinke, et al. (2004)^48^
SODAS City | Universal | Family | N = 43 community agencies in New York, New Jersey, and Delaware; 514 urban youth (1991-2010) RCT/NTC | At 7-year follow-up, lower past-month alcohol use, heavy drinking, and marijuana use. | Schinke, et al. (2010)^49^
I Hear What You're Saying | Universal (Mother-Daughter) | Family | Study 1: N = 591 adolescent girls and their mothers | Study 1: At 1 -year follow-up, reductions in use of alcohol, marijuana, and prescription drugs. | Schinke, et al. (2009)^50^
I Hear What You're Saying | Universal (Mother-Daughter) | Family | Study 2: N = 108 Asian American girls and their mothers (2007-2010) All studies: RCT/NTC | Study 2: At 2-year follow-up, reductions in use of alcohol, marijuana, and prescription drugs. | Fang & Schinke (2013)^51^
Familias Unidas | Universal/ Brief Version Selective | Family | Study 1:N = 160 Hispanic students in Grade 8 | Study 1: At 2-year follow-up, lower substance use initiation (28.6% vs. 65.2%) and substance use initiation (30.4% vs. 64.0%) among girls. | Estrada, et al. (2015)^52^
Familias Unidas | Universal/ Brief Version Selective | Family | Study 2: N = 213 Hispanic students in Grade 8 with behavior problems All studies: RCT/ TAU | Study 2: Significantly lower past 30-day substance use at 18-month (ES = 0.25) and 30-month follow-ups (25% vs. 34%). | Pantin, et al. (2009)^53^
Bicultural Competence Skills Program (BCSP) | Universal | Clinic/School | N = 27 public and tribal schools; 1,396 students from an American Indian Reservation in the Midwest (1986-1999) RCT/NTC | At 42-month follow-up, weekly alcohol use (22% vs. 30%) and weekly marijuana use (7 % vs. 15%) was lower in BCSP-only group. Results for a BCSP plus community group were not significant. | Schinke, et al. (2000)^54^
Project Chill | Universal | Primary Care | N = 7 urban health centers; 714 youth with no prior use aged 12 to 18 RCT/NTC | At 12-month follow-up, computer-based participants had lower rates of marijuana use at any point during the year (16.8% vs. 24.2%), but non-significant effect on 12 month use. No effects on alcohol. | Walton, et al. (2014)^55^
Positive Family Support (Family Check Up) | Selective | Family | N = 593 Grade 6-8 urban youth and their parents RCT/TAU | Lower rates of marijuana use through age 23. No effect on adult tobacco or alcohol use. | Véronneau, et al. (in press)^56^
Positive Family Support (Family Check Up) | Selective | Family | N = 593 Grade 6-8 urban youth and their parents RCT/TAU | For the 42% of families who engaged in the intervention, CACE analysis showed significantly less growth in tobacco, alcohol, and marijuana use across two years | Stormshak, et al. (2011)^57^
Keep Safe | Selective | School and Family | N = 100 girls in foster care entering middle school | At 18-month follow-up lower rate of substance use (ES = 0.47). | Kim et al (2011)^58^
Coping Power | Selective | School | Study 1: N = 245 high-aggression African American and White students in Grade 5 | Study 1: At 1 -year follow-up (7th grade), lower self-reported past-month use of substances (ES = 0.58). | Lochman & Wells (2003)^59^
Coping Power | Selective | School | Study 2: N = 183 high-aggression African American and White students in Grade 5 | Study 2: At 1 -year follow-up (7th grade), lower parent-reported substance use (ES = 0.31). | Lochman & Wells (2004)^60^
Coping Power | Selective | School | Study 3: N = 77 Dutch youth All Studies: RCT/ TAU | Study 3: At 4-year follow-up, lower use of marijuana (13% vs. 35%), no differences in alcohol use. | Zonnevylle, et al. (2007)^61^
Project Toward No Drug Abuse (TND) | Selective and Indicated | School | Study 1: N = 42 schools in Southern California; 2,468 high school students | Study 1: At 1 -year follow-up, reduction in levels of alcohol use among baseline users. | Sussman, et al. (2002)^62^
Project Toward No Drug Abuse (TND) | Selective and Indicated | School | Study 1: N = 42 schools in Southern California; 2,468 high school students | At 5-year follow-up, reduced hard drug use. | Sun, et al. (2006)^62^
Project Toward No Drug Abuse (TND) | Selective and Indicated | School | Study 2: N = 1,186 alternative high school students All studies: RCT/ TAU | Study 2: At 1-year follow-up, reductions in alcohol use (OR =0.68), drunkenness (OR = 0.67), and hard drug use (OR = 0.68). | Sussman, et al. (2012)^63^

Abbreviations: RCT - Randomized Controlled Trial, QED - Quasi-Experimental Design, TAU - Control Group Received Treatment As Usual, NTC - No Treatment Control, ES - Effect Size, OR - Odds Ratio

Table B.3 Evidence-Based Interventions for Age 18+

Intervention | Type (Universal, Selective, Indicated) | Domain/Level (Family, School, Workplace, Community, Multicomponent) | Sample (at pretest)/Ethnicity/Setting/Design | Summary Results | Citations: Key Outcome Research/Program Information Source
BASICS | Indicated | College | Study 1: N = 508 heavy drinking college freshmen | Study 1: At 1- and 2- year follow-ups, reductions in drinking frequency., At 4 year follow-up, reduction in drinking consequences. | Marlatt, et al. (1998)^64^ and Baer, et al. (2001)^65^
BASICS | Indicated | College | Study 2: N = 159 Fraternity-connected college students (81% White) | Study 2: At 1-year follow-up, reductions in average drinks per week (ES = 0.42) and typical peak BAC levels (ES = 0.38). | Larimer, et al. (2001)^66^
BASICS | Indicated | College | Study 3: N = 550 heavy drinking college students All studies: RCT/ TAU | Study 3: At 1-year follow-up, lower typical drinking (ES = 0.11) and peak drinking (ES = 0.42), and alcohol problem (ES = 0.56) for both volunteer and mandated students. | Terlecki, et al. (2015)^67^
Parent Handbook | Universal | College | Study 1: N = 882 college-bound students (79% White) | Study 1: At 8-month follow-up, females were less likely to transition into heavy drinking status, but males were more likely to do so. No effects on rate of alcohol-related problems. | Ichiyama, et al. (2009)^68^
Parent Handbook | Universal | College | Study 2: N = 1,900 college-bound students (87% White) | Study 2: Reduced the odds of continuing to be a heavy drinker for the first two years of college for students who came to campus with prior high-risk drinking habits (OR = 0.05). | Turrisi, et al. (2013)^69^
Parent Handbook | Universal | College | Study 3: N = 1,275 college-bound students, high-risk, athletes (80% White) All studies: RCT/NTC | Study 3: At 10-month follow-up, reduced alcohol peak consumption (ES = 0.26) .and alcohol-related consequences (ES = 0.20) for PH and BASICS combined. | Turrisi, et al. (2009)^70^
Parent Handbook | Universal | College | Study 3: N = 1,275 college-bound students, high-risk, athletes (80% White) All studies: RCT/NTC | At 22 months, reduction in the onset of alcohol consequences (ES = 0.21). No effect for PH alone. | Wood, et al. (2010)^71^
Yale Work and Family Stress Project | Universal | Workplace | N = 4 job sites; 239 primarily White female secretarial employees from Connecticut-based corporations RTC/NTC | At 22-month follow-up, reduced number of drinks per month. | Snow, et al. (2003)^72^
Brief Motivational Intervention in Emergency Department | Universal and Selective | Community | N = 539 injured patients treated in the ED; mostly males from urban, Southern New England (72% White) RCT/TAU | At 1-year follow-up, patients receiving brief intervention (BI) with booster reduced alcohol-related negative consequences and alcohol-related injuries; no differences were observed for heavy drinking days. No effects of BI without booster. | Longabaugh, et al. (2001)^73^
Team Awareness | Universal | Workplace | N = 235 employees in 28 restaurants RCT/NTC | At 1-year follow-up, the odds of recurring heavy drinking declined by 50%, and the number of work-related problem areas declined by one-third. | Broome and Bennett (2011)^74^
Computerized Alcohol-Related Problems Survey (CARPS) | Universal | Primary Care | N = 771 Primary care patients aged 65 and older RCT/TAU | At 1-year follow-up, participants decreased their harmful drinking 23% and increased their nonhazardous drinking 12%. | Fink, et al. (2008)^75^
Project Share | Selective | Primary Care | N = 1,186 Primary care patients aged 60 or older screened for at-risk drinking patterns RCT/TAU | At 1-year follow-up, and reductions in at-risk drinking (56% vs. 67%), lower rates of alcohol consumption. | Ettner, et al. (2014)^76^

Abbreviations: RCT - Randomized Controlled Trial, QED - Quasi-Experimental Design, TAU - Control Group Received Treatment As Usual, NTC - No Treatment Control, ES - Effect Size, OR - Odds Ratio

Table B.4 Evidence-Based Community Implementation Systems/ Coalition Models and Environmental Interventions

Intervention | Type (Universal, Selective, Indicated) | Domain/Level (Family, School, Community, Multicomponent) | Sample (at pretest)/Ethnicity/Setting/Design) | Summary Results | Citations: Key Outcome Research/Program Information Source
COMMUNITY COALITION MODELS
Communities That Care (CTC) | Universal | Multi-component | N = 24 communities in 7 States; 4,407 students in Grade 5 (20% Hispanic, 67% White, 3% African American) RCT/TAU | By Grade 10, students in CTC communities were less likely to initiate alcohol (OR = 0.62). At 10^th^ grade there were no differences rates of binge drinking or in past-month alcohol, marijuana, prescription, or other illicit drug use. | Hawkins, et al. (2012)^77^
Communities That Care (CTC) | Universal | Multi-component | N = 24 communities in 7 States; 4,407 students in Grade 5 (20% Hispanic, 67% White, 3% African American) RCT/TAU | By Grade 12, fewer CTC students had initiated any drug (OR = 0.71), alcohol (OR = 0.70), or cigarette (OR = 0.80) use. There were no differences in past-month or past-year alcohol, marijuana, or other illicit drug use, with the exception of higher rate of ecstasy use in the CTC condition. | Hawkins, et al. (2014)^78^
PROmoting School-community-university Partnerships to Enhance Resilience (PROSPER) | Universal | Multi-component | N = 28 rural and small town communities in Pennsylvania and Iowa;10,849 primarily White students in Grade 6 RCT/TAU | At 3.5-year and 4.5-year follow-up (Grades 11 and 12) youth in PROSPER communities showed lower past-year marijuana (13.5% reduction) and methamphetamine use (30.9% reduction). At Grade 12 only, PROSPER youth showed lower past-year inhalant use (28.3% reduction). Six-year growth curve effects lower for marijuana, amphetamine use, and drunkenness. | Spoth, et al. (2013a)^79^ and(2013b)^44^
PROmoting School-community-university Partnerships to Enhance Resilience (PROSPER) | Universal | Multi-component | N = 28 rural and small town communities in Pennsylvania and Iowa;10,849 primarily White students in Grade 6 RCT/TAU | By Grade 12, lower lifetime rates of prescription opioid misuse (22.1% vs. 27.8%) and lifetime prescription drug misuse overall (23.1% vs. 29.0%). | Spoth, et al. (2013a)^79^
Project Northland | Universal | Multi-component | N = 24 multiethnic urban, rural, and tribal school districts in Northern Minnesota RCT/TAU | The Phase 1 intervention was conducted when the targeted cohort was in Grade 6 to Grade 8. At 2.5 years past baseline, lower past-month and past-week alcohol use. | Phase 1: Perry, et al. (1996)^80^ and Klepp, et al. (1995)^81^
Project Northland | Universal | Multi-component | N = 24 multiethnic urban, rural, and tribal school districts in Northern Minnesota RCT/TAU | The Phase 2 intervention was conducted when the cohort was in Grade 11 toGrade 12. At 6.5 years past baseline, reductions in binge drinking. | Phase 2: Perry, et al. (2002)^82^
Project Star (Midwestern Prevention Project) | Universal | School and Community/Multicomponent | N = 42 urban public middle and junior high schools in Kansas City, Missouri and Indianapolis, Indiana; 3,412 White and African American students RCT/TAU | At 1-year follow-up, lower proportion of students reporting past-week and past-month use of alcohol. Secondary prevention effects on baseline users were observed up to 1.5 years past baseline, not at 2.5 and 3.5 years past baseline. Reductions in growth of amphetamine use through age 28. | Report 1: Pentz, et al. (1989)^83^ Report 2: Pentz & Valente (1993)^84^ Report 3: Pentz, et al. (1990)^85^ Report 4: Chou, et al. (1998)^86^ Report 5: Riggs, et al. (2009)^87^
ENVIRONMENTAL INTERVENTIONS
Reducing Underage Drinking Through State Coalitions | Universal | Community | N = National data from the Monitoring the Future Survey of students in Grades 8, 10, and 12 in ten states compared to all others QED | At posttest, significant effects in the proportion of Grade 8 and Grade 12 students reporting past month drunkenness (ES = 1.36; ES =1.29) and in Grade 12 students reporting binge drinking (ES = 2.18) and past year drinking (ES = 0.75). | Wagenaar, et al. (2006)^88^
Safer California Universities | Universal | Community | N=14 California universities; 19,791 students (49% White) RCT/TAU | At posttest, significant effects in the proportion of students reporting intoxication (ORs = 0.76 to 0.81). | Saltz, et al. (2010)^89^
Saving Lives | Universal | Community | N = 6 Massachusetts communities compared to all others in the state; 15,188 surveys of adults and youth aged 16 to 19 (90% White) QED | At posttest, a 42% reduction in fatal alcohol-related motor vehicle crashes and a 40% reduction in self-reported DUI among 16- to 19-year-olds. | Hingson, et al. (1996)^90^
Communities Mobilizing for Change on Alcohol | Universal | Community | Report 1: N = 15 Minnesota & Wisconsin communities | Report 1: At posttest, a 17% reduction in the proportion reporting that they provided alcohol to minors. | Wagenaar, et al. (2000)^91^
Communities Mobilizing for Change on Alcohol | Universal | Community | Report 2: N = 1,721-3,095 surveys of 18-20 year-olds (96% White) RCT/TAU | Report 2: At posttest, a reduction in the number of arrests for DUI. | Wagenaar, et al. (2000)^92^
Study to Prevent Alcohol Related Consequences (SPARC) | Universal | Community | N = 10 colleges/universities in North Carolina; 3,811 students (80% White) RCT/TAU | At posttest, signification reductions in student reports of alcohol-related personal harms and causing injuries to others. | Wolfson, et al. (2012)^93^
Sacramento Neighborhood Alcohol Prevention Project (SNAPP) | Selective | Community | N = 2 low-income communities compared to all others in the city (35% Hispanic, 18% African American) QED | At posttest, fewer arrests for assaults (ES = 0.48), Emergency Medical Services (EMS) calls for assaults (ES = 0.57), and car accidents (ES = 0.55). | Treno, et al. (2007)^94^

Abbreviations: RCT - Randomized Controlled Trial, QED - Quasi-Experimental Design, TAU - Control Group Received Treatment As Usual, NTC - No Treatment Control, ES - Effect Size, OR - Odds Ratio

Table B.5 Community Preventive Services Task Force Recommendations for Preventing Alcohol Misuse

Policy Interventions
Increase Alcohol Taxes
Regulate Alcohol Outlet Density
Dram Shop (Commercial Host ) Liability
Avoid Further Privatization of Alcohol Sales
Maintain Limits on Days of Sale
Maintain Limits on Hours of Sale
Enhanced Enforcement of Laws Prohibiting Sales to Minors
Electronic Screening and Brief Intervention (e-SBI)

Source: Community Preventive Services Task Force, (2016).^95^

## References

1 Olds D, Henderson CR, Cole R, Eckenrode J, Kitzman H, Luckey D, Powers J. (1998). Long-term effects of nurse home visitation on children's criminal and antisocial behavior: 15-year follow-up of a randomized controlled trial. Journal of the American Medical Association.
2 Eckenrode J, Campa M, Luckey DW, Henderson CR, Cole R, Kitzman H, Olds D. (2010). Long-term effects of prenatal and infancy nurse home visitation on the life course of youths: 19-year follow-up of a randomized trial. Archives of Pediatrics and Adolescent Medicine.
3 Kitzman HJ, Olds DL, Cole RE, Hanks CA, Anson EA, Arcoleo KJ, Holmberg JR. (2010). Enduring effects of prenatal and infancy home visiting by nurses on children: follow-up of a randomized trial among children at age 12 years. Archives of pediatrics & adolescent medicine.
4 Hawkins JD, Catalano RF, Morrison DM, O'Donnell J, Abbott RD, Day LE. (1992). The Seattle Social Development Project: Effects of the first four years on protective factors and problem behaviors. McCord J, Tremblay RE, editors. Preventing antisocial behavior: Interventions from birth through adolescence.
5 Hawkins JD, Catalano RF, Kosterman R, Abbott R, Hill KG. (1999). Preventing adolescent health-risk behaviors by strengthening protection during childhood. Archives of Pediatrics and Adolescent Medicine.
6 Hawkins JD, Kosterman R, Catalano RF, Hill KG, Abbott RD. (2005). Promoting positive adult functioning through social development intervention in childhood: Long-term effects from the Seattle Social Development Project. Archives of Pediatrics & Adolescent Medicine.
7 Hawkins JD, Kosterman R, Catalano RF, Hill KG, Abbott RD. (2008). Effects of social development intervention in childhood 15 years later. Archives of Pediatrics and Adolescent Medicine.
8 Brown EC, Catalano RF, Fleming CB, Haggerty KP, Abbott RD. (2005). Adolescent substance use outcomes in the Raising Healthy Children project: A two-part latent growth curve analysis. Journal of Consulting and Clinical Psychology.
9 Kellam SG, Brown CH, Poduska JM, Ialongo NS, Wang W, Toyinbo P, Wilcox HC. (2008). Effects of a universal classroom behavior management program in first and second grades on young adult behavioral, psychiatric, and social outcomes. Drug and Alcohol Dependence.
10 Kellam SG, Wang W, Mackenzie ACL, Brown CH, Ompad DC, Or F, Windham A. (2014). The impact of the Good Behavior Game, a universal classroom-based preventive intervention in first and second grades, on high-risk sexual behaviors and drug abuse and dependence disorders into young adulthood. Prevention Science.
11 Ialongo N, Poduska J, Werthamer L, Kellam S. (2001). The distal impact of two first-grade preventive interventions on conduct problems and disorder in early adolescence. Journal of Emotional and Behavioral Disorders.
12 Furr-Holden CDM, Ialongo NS, Anthony JC, Petras H, Kellam SG. (2004). Developmentally inspired drug prevention: Middle school outcomes in a school-based randomized prevention trial. Drug and Alcohol Dependence.
13 Liu W, Lynne-Landsman SD, Petras H, Masyn K, Ialongo N. (2013). The evaluation of two first-grade preventive interventions on childhood aggression and adolescent marijuana use: A latent transition longitudinal mixture model. Prevention Science.
14 Eddy JM, Reid JB, Stoolmiller M, Fetrow RA. (2003). Outcomes during middle school for an elementary school-based preventive intervention for conduct problems: Follow-up results from a randomized trial. Behavior Therapy.
15 DeGarmo DS, Eddy JM, Reid JB, Fetrow RA. (2009). Evaluating mediators of the impact of the Linking the Interests of Families and Teachers (LIFT) multimodal preventive intervention on substance use initiation and growth across adolescence. Prevention Science.
16 Dodge KA, Bierman KL, Coie JD, Greenberg MT, Lochman JE, McMahon RJ, Pinderhughes EE. (2014). Impact of early intervention on psychopathology, crime, and well-being at age 25. American Journal of Psychiatry.
17 Tremblay RE, Masse LC, Pagani L, Vitaro F. (1996). From childhood physical aggression to adolescent maladjustment: The Montreal Prevention Experiment. Peters RD, McMahon RJ, editors. Preventing childhood disorders, substance abuse, and delinquency.
18 Masse LC. (1996). From childhood physical aggression to adolescent maladjustment. Preventing childhood disorders, substance abuse, and delinquency.
19 Botvin GJ, Baker E, Dusenbury L, Botvin EM, Diaz T. (1995). Long-term follow-up results of a randomized drug abuse prevention trial in a white middle-class population. JAMA.
20 Botvin GJ, Griffin KW, Diaz T, Ifill-Williams M. (2001). Preventing binge drinking during early adolescence: One-and two-year follow-up of a school-based preventive intervention. Psychology of Addictive Behaviors.
21 Griffin KW, Botvin GJ, Nichols TR, Doyle MM. (2003). Effectiveness of a universal drug abuse prevention approach for youth at high risk for substance use initiation. Preventive Medicine.
22 Smith EA, Swisher JD, Vicary JR, Bechtel LJ, Minner D, Henry KL, Palmer R. (2004). Evaluation of Life Skills Training and Infused-Life Skills Training in a rural setting: Outcomes at two years. Journal of Alcohol and Drug Education.
23 Spoth R, Randall GK, Shin C, Redmond C. (2005). Randomized study of combined universal family and school preventive interventions: Patterns of long-term effects on initiation, regular use, and weekly drunkenness. Psychology of Addictive Behaviors.
24 Spoth RL, Clair S, Shin C, Redmond C. (2006). Long-term effects of universal preventive interventions on methamphetamine use among adolescents. Archives of Pediatrics and Adolescent Medicine.
25 Spoth RL, Randall GK, Trudeau L, Shin C, Redmond C. (2008). Substance use outcomes 5½ years past baseline for partnership-based, family-school preventive interventions. Drug and Alcohol Dependence.
26 McBride N, Midford R, Farringdon F, Phillips M. (2000). Early results from a school alcohol harm minimization study: The School Health and Alcohol Harm Reduction Project. Addiction.
27 McBride N, Farringdon F, Midford R, Meuleners L, Phillips M. (2004). Harm minimization in school drug education: Final results of the School Health and Alcohol Harm Reduction Project (SHAHRP). Addiction.
28 Conrod PJ, Castellanos-Ryan N, Strang J. (2010). Brief, personality-targeted coping skills interventions and survival as a non-drug user over a 2-year period during adolescence. Archives of General Psychiatry.
29 Conrod PJ, Castellanos-Ryan N, Mackie C. (2011). Long-term effects of a personality-targeted intervention to reduce alcohol use in adolescents. Journal of Consulting and Clinical Psychology.
30 Conrod PJ, O'Leary-Barrett M, Newton N, Topper L, Castellanos-Ryan N, Mackie C, Girard A. (2013). Effectiveness of a selective, personality-targeted prevention program for adolescent alcohol use and misuse: A cluster randomized controlled trial. JAMA Psychiatry.
31 Mahu IT, Doucet C, O'Leary-Barrett M, Conrod PJ. (2015). Can cannabis use be prevented by targeting personality risk in schools? 24-month outcome of the adventure trial on cannabis use: A cluster randomized controlled trial. Addiction.
32 Lammers J, Goossens F, Conrod P, Engels R, Wiers RW, Kleinjan M. (2015). Effectiveness of a selective intervention program targeting personality risk factors for alcohol misuse among young adolescents: Results of a cluster randomized controlled trial. Addiction.
33 Faggiano F, Vigna-Taglianti F, Burkhart G, Bohrn K, Cuomo L, Gregori D, Varona L. (2010). The effectiveness of a school-based substance abuse prevention program: 18-month follow-up of the EU-Dap cluster randomized controlled trial. Drug and Alcohol Dependence.
34 Hecht ML, Marsiglia FF, Elek E, Wagstaff DA, Kulis S, Dustman P, Miller-Day M. (2003). Culturally grounded substance use prevention: An evaluation of the keepin'it REAL curriculum. Prevention Science.
35 Hecht ML, Graham JW, Elek E. (2006). The drug resistance strategies intervention: Program effects on substance use. Health Communication.
36 Kulis S, Marsiglia FF, Sicotte D, Nieri T. (2007). Neighborhood effects on youth substance use in a southwestern city. Sociological Perspectives.
37 Marsiglia FF, Ayers S, Gance-Cleveland B, Mettler K, Booth J. (2012). Beyond primary prevention of alcohol use: A culturally specific secondary prevention program for Mexican heritage adolescents. Prevention Science.
38 Goldberg L, MacKinnon DP, Elliot DL, Moe EL, Clarke G, Cheong J. (2000). The adolescents training and learning to avoid steroids program: Preventing drug use and promoting health behaviors. Archives of Pediatrics and Adolescent Medicine.
39 Spoth RL, Redmond C, Shin C. (2001). Randomized trial of brief family interventions for general populations: Adolescent substance use outcomes 4 years following baseline. Journal of Consulting and Clinical Psychology.
40 Spoth R, Redmond C, Shin C, Azevedo K. (2004). Brief family intervention effects on adolescent substance initiation: School-level growth curve analyses 6 years following baseline. Journal of Consulting and Clinical Psychology.
41 Spoth R, Trudeau L, Guyll M, Shin C, Redmond C. (2009). Universal intervention effects on substance use among young adults mediated by delayed adolescent substance initiation. Journal of Consulting and Clinical Psychology.
42 Spoth RL, Trudeau LS, Guyll M, Shin C. (2012). Benefits of universal intervention effects on a youth protective shield 10 years after baseline. Journal of Adolescent Health.
43 Spoth RL, Redmond C, Trudeau L, Shin C. (2002). Longitudinal substance initiation outcomes for a universal preventive intervention combining family and school programs. Psychology of Addictive Behaviors.
44 Spoth R, Trudeau L, Shin C, Ralston E, Redmond C, Greenberg M, Feinberg M. (2013). Longitudinal effects of universal preventive intervention on prescription drug misuse: Three randomized controlled trials with late adolescents and young adults. American Journal of Public Health.
45 Mason WA, Kosterman R, Haggerty KP, Hawkins JD, Redmond C, Spoth RL, Shin C. (2009). Gender moderation and social developmental mediation of the effect of a family-focused substance use preventive intervention on young adult alcohol abuse. Addictive Behaviors.
46 Brody GH, Murry VM, Kogan SM, Gerrard M, Gibbons FX, Molgaard V, Wills TA. (2006). The Strong African American Families Program: A cluster-randomized prevention trial of long-term effects and a mediational model. Journal of Consulting and Clinical Psychology.
47 Brody GH, Chen Y-F, Kogan SM, Murry VM, Brown AC. (2010). Long-term effects of the Strong African American Families program on youths' alcohol use. Journal of Consulting and Clinical Psychology.
48 Schinke SP, Schwinn TM, Di Noia J, Cole KC. (2004). Reducing the risks of alcohol use among urban youth: Three-year effects of a computer-based intervention with and without parent involvement. Journal of Studies on Alcohol.
49 Schinke SP, Schwinn TM, Fang L. (2010). Longitudinal outcomes of an alcohol abuse prevention program for urban adolescents. Journal of Adolescent Health.
50 Schinke SP, Fang L, Cole KC. (2009). Computer-delivered, parent-involvement intervention to prevent substance use among adolescent girls. Preventive Medicine.
51 Fang L, Schinke SP. (2013). Two-year outcomes of a randomized, family-based substance use prevention trial for Asian American adolescent girls. Psychology of Addictive Behaviors.
52 Estrada Y, Rosen A, Huang S, Tapia M, Sutton M, Willis L, Prado G. (2015). Efficacy of a brief intervention to reduce substance use and Q1 human immunodeficiency virus infection risk among Latino youth. Journal of Adolescent Health.
53 Pantin H, Prado G, Lopez B, Huang S, Tapia MI, Schwartz SJ, Branchini J. (2009). A randomized controlled trial of Familias Unidas for Hispanic adolescents with behavior problems. Psychosomatic Medicine.
54 Schinke SP, Tepavac L, Cole KC. (2000). Preventing substance use among Native American youth: Three-year results. Addictive Behaviors.
55 Walton MA, Resko S, Barry KL, Chermack ST, Zucker RA, Zimmerman MA, Blow FC. (2014). A randomized controlled trial testing the efficacy of a brief cannabis universal prevention program among adolescents in primary care. Addiction.
56 Veronneau MH, Dishion TJ, Connell AM. 10 year ITT effects on marijuana use. Journal of Consulting and Clinical Psychology.
57 Stormshak EA, Connell AM, Véronneau MH, Myers MW, Dishion TJ, Kavanagh K, Caruthers AS. (2011). An ecological approach to promoting early adolescent mental health and social adaptation: Family-centered intervention in public middle schools. Child Development.
58 Kim HK, Leve LD. (2011). Substance use and delinquency among middle school girls in foster care: A three-year follow-up of a randomized controlled trial. Journal of Consulting and Clinical Psychology.
59 Lochman JE, Wells KC. (2003). Effectiveness of the Coping Power Program and of classroom intervention with aggressive children: Outcomes at a 1-year follow-up. Behavior Therapy.
60 Lochman JE, Wells KC. (2004). The coping power program for preadolescent aggressive boys and their parents: Outcome effects at the 1-year follow-up. Journal of Consulting and Clinical Psychology.
61 Zonnevylle-Bender MJS, Matthys W, Lochman JE. (2007). Preventive effects of treatment of disruptive behavior disorder in middle childhood on substance use and delinquent behavior. Journal of the American Academy of Child & Adolescent Psychiatry.
62 Sun W, Skara S, Sun P, Dent CW, Sussman S. (2006). Project Towards No Drug Abuse: Long-term substance use outcomes evaluation. Preventive Medicine.
63 Sussman S, Sun P, Rohrbach LA, Spruijt-Metz D. (2012). One-year outcomes of a drug abuse prevention program for older teens and emerging adults: Evaluating a motivational interviewing booster component. Health Psychology.
64 Marlatt GA, Baer JS, Kivlahan DR, Dimeff LA, Larimer ME, Quigley LA, Williams E. (1998). Screening and brief intervention for high-risk college student drinkers: Results from a 2-year follow-up assessment. Journal of Consulting and Clinical Psychology.
65 Baer JS, Kivlahan DR, Blume AW, McKnight P, Marlatt GA. (2001). Brief intervention for heavy-drinking college students: 4-year follow-up and natural history. American Journal of Public Health.
66 Larimer ME, Turner AP, Anderson BK, Fader JS, Kilmer JR, Palmer RS, Cronce JM. (2001). Evaluating a brief alcohol intervention with fraternities. Journal of Studies on Alcohol.
67 Terlecki MA, Buckner JD, Larimer ME, Copeland AL. (2015). Randomized controlled trial of brief alcohol screening and intervention for college students for heavy-drinking mandated and volunteer undergraduates: 12-month outcomes. Psychology of Addictive Behaviors.
68 Ichiyama MA, Fairlie AM, Wood MD, Turrisi R, Francis DP, Ray AE, Stanger LA. (2009). A randomized trial of a parent-based intervention on drinking behavior among incoming college freshmen. Journal of Studies on Alcohol and Drugs Supplement.
69 Turrisi R, Mallett KA, Cleveland MJ, Varvil-Weld L, Abar C, Scaglione N, Hultgren B. (2013). Evaluation of timing and dosage of a parent-based intervention to minimize college students' alcohol consumption. Journal of Studies on Alcohol and Drugs.
70 Turrisi R, Larimer ME, Mallett KA, Kilmer JR, Ray AE, Mastroleo NR, Montoya H. (2009). A randomized clinical trial evaluating a combined alcohol intervention for high-risk college students. Journal of Studies on Alcohol and Drugs.
71 Wood MD, Fairlie AM, Fernandez AC, Borsari B, Capone C, Laforge R, Carmona-Barros R. (2010). Brief motivational and parent interventions for college students: A randomized factorial study. Journal of Consulting and Clinical Psychology.
72 Snow DL, Swan SC, Wilton L. (2003). A workplace coping-skills intervention to prevent alcohol abuse. Bennett JB, Lehman WEK, editors. Preventing workplace substance abuse: Beyond drug testing to wellness.
73 Longabaugh R, Woolard RE, Nirenberg TD, Minugh AP, Becker B, Clifford PR, Gogineni A. (2001). Evaluating the effects of a brief motivational intervention for injured drinkers in the emergency department. Journal of Studies on Alcohol.
74 Broome KM, Bennett JB. (2011). Reducing heavy alcohol consumption in young restaurant workers. Journal of Studies on Alcohol and Drugs.
75 Fink A, Elliott MN, Tsai M, Beck JC. (2008). An evaluation of an intervention to assist primary care physicians in screening and educating older patients who use alcohol: Erratum. Journal of the American Geriatrics Society.
76 Ettner SL, Xu H, Duru OK, Ang A, Tseng C-H, Tallen L, Moore AA. (2014). The effect of an educational intervention on alcohol consumption, at-risk drinking, and health care utilization in older adults: The Project SHARE study. Journal of Studies on Alcohol and Drugs.
77 Hawkins JD, Oesterle S, Brown EC, Monahan KC, Abbott RD, Arthur MW, Catalano RF. (2012). Sustained decreases in risk exposure and youth problem behaviors after installation of the Communities That Care prevention system in a randomized trial. Archives of Pediatrics & Adolescent Medicine.
78 Hawkins JD, Oesterle S, Brown EC, Abbott RD, Catalano RF. (2014). Youth problem behaviors 8 years after implementing the Communities That Care prevention system: A community-randomized trial. JAMA Pediatrics.
79 Spoth R, Redmond C, Shin C, Greenberg M, Feinberg M, Schainker L. (2013). PROSPER community-university partnership delivery system effects on substance misuse through 6 1/2years past baseline from a cluster randomized controlled intervention trial. Preventive Medicine.
80 Perry CL, Williams CL, Veblen-Mortenson S, Toomey TL, Komro KA, Anstine PS, Wagenaar AC. (1996). Project Northland: Outcomes of a communitywide alcohol use prevention program during early adolescence. American Journal of Public Health.
81 Klepp K-I, Kelder SH, Perry CL. (1995). Alcohol and marijuana use among adolescents: Long-term outcomes of the Class of 1989 Study. Annals of Behavioral Medicine.
82 Perry CL, Williams CL, Komro KA, Veblen-Mortenson S, Stigler MH, Munson KA, Forster JL. (2002). Project Northland: Long-term outcomes of community action to reduce adolescent alcohol use. Health Education Research.
83 Pentz MA, Dwyer JH, MacKinnon DP, Flay BR, Hansen WB, Wang EYI, Johnson CA. (1989). A multicommunity trial for primary prevention of adolescent drug abuse: Effects on drug use prevalence. JAMA.
84 Pentz MA, Valente T. (1993). Project STAR: A substance abuse prevention campaign in Kansas City. Backer TE, Rogers EM, editors. Organizational aspects of health communication campaigns: What works?.
85 Pentz MA, Trebow EA, Hansen WB, MacKinnon DP, Dwyer JH, Johnson CA, Cormack C. (1990). Effects of program implementation on adolescent drug use behavior: The Midwestern Prevention Project (MPP). Evaluation Review.
86 Chou C-P, Montgomery S, Pentz MA, Rohrbach LA, Johnson CA, Flay BR, MacKinnon DP. (1998). Effects of a community-based prevention program on decreasing drug use in high-risk adolescents. American Journal of Public Health.
87 Riggs NR, Chou CP, Pentz MA. (2009). Preventing growth in amphetamine use: Long-term effects of the Midwestern Prevention Project (MPP) from early adolescence to early adulthood. Addiction.
88 Wagenaar AC, Erickson DJ, Harwood EM, O'Malley PM. (2006). Effects of state coalitions to reduce underage drinking: A national evaluation. American Journal of Preventive Medicine.
89 Saltz RF, Paschall MJ, McGaffigan RP, Nygaard PMO. (2010). Alcohol risk management in college settings: The Safer California Universities randomized trial. American Journal of Preventive Medicine.
90 Hingson R, McGovern T, Howland J, Heeren T, Winter M, Zakocs RC. (1996). Reducing alcohol-impaired driving in Massachusetts: The Saving Lives program. American Journal of Public Health.
91 Wagenaar AC, Murray DM, Gehan JP, Wolfson M, Forster JL, Toomey TL, Jones-Webb R. (2000). Communities Mobilizing For Change on Alcohol: Outcomes from a randomized community trial. Journal of Studies on Alcohol.
92 Wagenaar AC, Murray DM, Toomey TL. (2000). Communities Mobilizing for Change on Alcohol (CMCA): Effects of a randomized trial on arrests and traffic crashes. Addiction.
93 Wolfson M, Champion H, McCoy TP, Rhodes SD, Ip EH, Blocker JN, Durant RH. (2012). Impact of a randomized campus/community trial to prevent high-risk drinking among college students. Alcoholism: Clinical and Experimental Research.
94 Treno AJ, Gruenewald PJ, Lee JP, Remer LG. (2007). The Sacramento Neighborhood Alcohol Prevention Project: Outcomes from a community prevention trial. Journal of Studies on Alcohol and Drugs.
95 Community Preventive Services Task Force. (2016). Preventing excessive alcohol consumption. The guide to community preventive services: The community guide.