# APPENDIX A REVIEW PROCESS FOR PREVENTION PROGRAMS

## Sources and Process

The review of published research primarily focused on refereed, professional journals, which were searched using PubMed and PsycINFO. Government reports, annotated bibliographies, and relevant books and book chapters also were reviewed. In addition, programs were searched on SAMHSA's National Registry of Evidence-based Programs and Practices (NREPP) and the Centers for Disease Control and Prevention (CDC) Guide to Community Preventive Services. From these collective sources, a set of 600 core prevention programs was identified for possible inclusion in this Report. Of those, 42 met the evaluation criteria listed below and were included.

## Evaluation Criteria

Programs were included only if they met the program criteria of the Blueprints for Healthy Youth Development listed below. All of these programs fit within CDC's well-supported category.

- Experimental design: All programs were evaluated using a randomized trial design or a quasi-experimental design that used an adequate comparison group. The prevention effects described compare the group or individuals that got the prevention intervention with those who did not.
- Sample specification: The behavioral and social characteristics of the sample for which outcomes were measured must have been specified.
- Outcome assessments: These assessments must have included pretest, posttest, and follow-up findings. The need for follow-up findings was considered essential given the frequently observed dissipation of positive posttest results. Follow-up data had to be reported more than 6 months beyond the time point at which the primary components of the intervention were delivered, in order to examine the duration and stability of intervention effects.
- Effects: Independent of whether the prevention intervention began prenatally, in the early years of life, or in adolescence or adulthood, programs were included only if they produced outcomes showing a measurable difference in substance use or substance use-related outcomes between intervention and comparison groups based on statistical significance testing. Level of significance and the size of the effects are reported in Appendix B - Evidence-Based Prevention Programs and Policies. Programs that broadly affected other behavioral health problems but did not show reductions in at least one direct measure of substance use were excluded.
- Additional quality of evidence criteria: The program provided evidence that seven quality of evidence criteria consistent with those of NREPP^i^ were met: (1) reliability of outcome measures, (2) validity of outcome measures, (3) pretest equivalence, (4) intervention fidelity, (5) analysis of missing data, (6) degree and evaluation of sample attrition, and (7) appropriate statistical analyses.
- Operations Manual: The program had a written manual that specified the procedures used in the intervention to increase likelihood that the prevention intervention would be replicated with fidelity.

For more on this topic

See Chapter 1 - Introduction and Overview.

i Substance Abuse and Mental Health Services Administration. National registry of evidence-based programs and practices (NREPP). .