# LIST OF ABBREVIATIONS

Abbreviation: Definition
AA: Alcoholics Anonymous
ACC: Accountable Care Community
ACO: Accountable Care Organization
AIDS: Acquired Immune Deficiency Syndrome
ASAM: American Society of Addiction Medicine
ASI: Addiction Severity Index
AUDIT: Alcohol Use Disorders Identification Test
BAC: Blood Alcohol Content
BASICS: Brief Alcohol Screening and Intervention for College Students
BNST: Bed Nucleus of the Stria Terminalis
BRAIN: Brain Research through Advancing Innovative Neurotechnologies
CADCA: Community Anti-Drug Coalitions of America
CARA: Comprehensive Addiction and Recovery Act
CARPS: Computerized Alcohol-Related Problems Survey
CBT: Cognitive Behavioral Therapy
CCO: Coordinated Care Organization
CDC: Centers for Disease Control and Prevention
CeA: Central Nucleus of the Amygdala
CHIP: Children's Health Insurance Program
CIDI: Composite International Diagnostic Interview
CMCA: Communities Mobilizing for Change on Alcohol
CMS: Centers for Medicare & Medicaid Services
CRF: Corticotropin-Releasing Factor
CSA: Controlled Substances Act
CTC: Communities That Care
DEA: Drug Enforcement Administration
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition
DSM-5: Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition
DUI: Driving Under the Influence
DS: Dorsal Striatum
EBI: Evidence-Based Interventions
EHR: Electronic Health Record
FASD: Fetal Alcohol Spectrum Disorder
FBT: Family Behavior Therapy
FDA: Food and Drug Administration
FQHC: Federally Qualified Health Center
GABA: Gamma-Aminobutyric Acid
HEDIS: Healthcare Effectiveness Data and Information Set
HHS: U.S. Department of Health and Human Services
HIPAA: Health Insurance Portability and Accountability Act
HIV: Human Immunodeficiency Virus
HRSA: Health Resources and Services Administration
ICCPUD: Interagency Coordinating Committee on the Prevention of Underage Drinking
IOM: Institute of Medicine, now known as the Health and Medicine Division of the National Academies of Science, Engineering, and Medicine
LGBT: Lesbian, Gay, Bisexual, and Transgender
LST: Life Skills Training
MADD: Mothers Against Drunk Driving
MET: Motivational Enhancement Therapy
MHPAEA: Paul Wellstone and Pete Domenici Mental Health Parity and Addiction Equity Act of 2008
MLDA: Minimum Legal Drinking Age
MRI: Magnetic Resonance Imaging
NA: Narcotics Anonymous
NAc: Nucleus Accumbens
NASPER: National All Schedules Prescription Electronic Reporting Act
NFP: Nurse-Family Partnership Program
NHTSA: National Highway Traffic Safety Administration
NIAAA: National Institute on National Institute on Alcohol Abuse and Alcoholism
NIDA: National Institute on Drug Abuse
NIH: National Institutes of Health
NREPP: National Registry of Evidence-based Programs and Practices
NSDUH: National Survey on Drug Use and Health
OTP: Opioid Treatment Program
PDMP: Prescription Drug Monitoring Program
PET: Positron Emission Tomography
PFC: Prefrontal Cortex
PRISM: Psychiatric Research Interview for Substance and Mental Disorders
PROSPER: PROmoting School-community-university Partnerships to Enhance Resilience
PTSD: Post-Traumatic Stress Disorder
QALY: Quality-Adjusted Life Year
RHC: Raising Healthy Children
RMC: Recovery Management Check-up
RSS: Recovery Support Services
SAMHSA: Substance Abuse and Mental Health Services Administration
SBI: Screening and Brief Intervention
SBIRT: Screening, Brief Intervention, and Referral to Treatment
SFP: Strengthening Families Program
SIM: State Innovation Models
SPA: State Plan Amendment
THC: Δ^9^-tetrahydrocannabinol
USPSTF: U.S. Preventive Services Task Force
VTA: Ventral Tegmental Area