# Preface, from the Surgeon General

In 1964, the year of the first Surgeon General’s report on smoking and health, nearly one in two U.S. adults smoked cigarettes. We’ve made remarkable progress since then. Today, about one in nine adults smokes cigarettes. Sixty years later, the elimination of all tobacco-related disease and death for our nation is a bold yet attainable goal.

To reach this ambitious public health goal, we must first acknowledge that progress has not been even. In his 1998 report, then U.S. Surgeon General Dr. David Satcher marked a historic step in recognizing the disproportionate burdens of tobacco-related disease, disability, and death among certain racial and ethnic groups (U.S. Department of Health and Human Services [USDHHS] 1998). Today, as we show in this report, cigarette smoking among men and women living in poverty is more than twice as common compared to those not living in poverty. American Indian and Alaska Native adults and youth have the highest prevalence of cigarette smoking by race and ethnicity in the United States, and among people who do not smoke, exposure to secondhand tobacco smoke remains disproportionately higher among Black people than among people in other racial and ethnic groups. Youth who identify as lesbian, gay, or bisexual have a prevalence of cigarette smoking that is nearly double that of their heterosexual peers. The gap in tobacco use between youth living in rural areas and those living in urban areas has widened since 1998. Across the country, income, race and ethnicity, level of education, sexual orientation and gender identity, geography, and mental health play a significant role in determining who uses tobacco and who suffers from its harmful health consequences.

Industry-designed tobacco products such as menthol cigarettes and flavored cigars also contribute to tobacco-related health disparities. Today, the tobacco industry continues to outspend tobacco control efforts by a factor of at least 12 to 1 annually with more than $8.5 billion spent in tobacco-related advertising and promotion (Campaign for Tobacco-Free Kids 2023; Federal Trade Commission 2023a,b).

It doesn’t have to be this way. We have the chance and the choice to free our society from tobacco industry influence and create a tobacco-free America for all. This Surgeon General’s report—the 35th on smoking and health—summarizes key progress at national, state, and local levels toward eliminating tobacco-related disparities in the United States. Protecting public health for the whole population, including eliminating disparities, requires equitable access to evidence-based strategies, such as cessation programs and quitlines; mass media campaigns; and retail, product, and marketing regulations. There are additional concrete steps we can support today. A product standard that establishes a maximum nicotine yield to reduce the addictiveness of cigarettes and other combusted tobacco products could prevent more than 33 million people from starting to smoke, avert more than 8 million deaths, and result in an adult smoking prevalence of under 2% by year 2100 (Apelberg et al. 2018). A product standard to prohibit the sales and marketing of menthol cigarettes could avert up to 654,000 deaths over the next four decades (Levy et al. 2023). As of 2024, two states and nearly 200 U.S. communities prohibit the sale of menthol cigarettes and other flavored tobacco products, protecting about one-sixth of the population (Truth Initiative 2023; Campaign for Tobacco-Free Kids 2024). And, in the boldest step yet, two communities have chosen to eliminate the sale of all commercial tobacco products (City of Beverly Hills 2019; Action on Smoking & Health 2020; City of Manhattan Beach n.d.). Importantly and appropriately, these strategies focus on product manufacturing, distribution, and sales—and do not include a prohibition on individual consumer possession or use.

Today, cigarette smoking and exposure to secondhand tobacco smoke continue to cause nearly half a million deaths in the United States each year—nearly one in five of all deaths. It is difficult to adequately describe the profound human toll of these deaths on loved ones who are left behind. The financial consequences of tobacco-related death and disease are also staggering—nearly $600 billion in healthcare spending and lost economic productivity in 2018 (Shrestha et al. 2022). More work remains to close key gaps and finally eliminate the leading cause of preventable disease and death for Americans today. This report offers a vision for a tobacco-free future, focused on those who bear the greatest burden, and a call to action for all sectors of society to realize that vision.

As a father of two young children, few things are more important to me than ensuring they have the best possible chance of good health and a bright future. I want this for all our kids. I believe the vast majority of Americans feel the same about our sacred responsibility to protect our kids. Nine in 10 adults who smoke began smoking as youth (USDHHS 2012, 2014). Children should not have to worry about a multibillion-dollar commercial tobacco industry that profits at the expense of their health. The time is now to accelerate a whole-of-society effort to reach the tobacco endgame: a world in which zero lives are harmed by or lost to tobacco use. By driving down the appeal, availability, and addictiveness of tobacco products, we can make this more than just a possibility. We can make it a reality. Can we summon the moral courage as a nation to do so, for one another, for our children, and for generations to come?

Vivek H. Murthy, M.D., M.B.A. Vice Admiral, U.S. Public Health Service Surgeon General of the United States

## References

Action on Smoking & Health. Beverly Hills and Manhattan Beach, California make history for public health, January 5, 2020; <https://ash.org/california-jan1-2021/>; accessed: February 22, 2024.
Apelberg BJ, Feirman SP, Salazar E, Corey CG, Ambrose BK, Paredes A, Richman E, Verzi SJ, Vugrin ED, Brodsky NS, . Potential public health effects of reducing nicotine levels in cigarettes in the United States. New England Journal of Medicine 2018;378(18):1725–33.29543114
Campaign for Tobacco-Free Kids. States & Localities That Have Restricted the Sale of Flavored Tobacco Products, October 3, 2024; <https://assets.tobaccofreekids.org/factsheets/0398.pdf>; accessed: October 30, 2024.
Campaign for Tobacco-Free Kids. State Tobacco Prevention Spending vs. Tobacco Company Marketing, December 22, 2023; <https://www.tobaccofreekids.org/assets/content/what_we_do/state_local_issues/settlement/FY2023/5-State-Tobacco-Prevention-Spending-vs-Tobacco-Company-Marketing.pdf>; accessed: February 22, 2024.
Centers for Disease Control and Prevention. Tobacco Product Use Among Adults—United States, 2022, September 10, 2024; <https://www.cdc.gov/tobacco/media/pdfs/2024/09/cdc-osh-ncis-data-report-508.pdf>; accessed: October 24, 2024.
City of Beverly Hills. Beverly Hills City Council approves prohibiting the sale of all tobacco products, June 4, 2019; <https://www.beverlyhills.org/cbhfiles/storage/files/1913332427980555715/Tobacco6419.pdf>; accessed: February 22, 2024.
City of Manhattan Beach. Smoke free MB, n.d.; <https://www.manhattanbeach.gov/departments/environmental-sustainability/breathe-free-mb-smoke-free-public-areas>; accessed: February 22, 2024.
Federal Register. U.S. Department of Health and Human Services, Food and Drug Administration. Tobacco product standard for menthol in cigarettes, proposed rule (21 CFR 1162), 87 Fed. Reg. 26454 (2022a).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Proposed rule, tobacco product standard for nicotine level of combusted cigarettes (21 CFR 1130), 83 Fed. Reg. 11818 (2018).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Proposed rule: tobacco product standard for characterizing flavors in cigars (21 CFR 1166), 87 Fed. Reg. 26396 (2022b).
Federal Trade Commission. Federal Trade Commission Cigarette Report for 2022, 2023a; <https://www.ftc.gov/system/files/ftc_gov/pdf/2022-Cigarette-Report.pdf>; accessed: February 22, 2024.
Federal Trade Commission. Federal Trade Commission Smokeless Tobacco Report for 2022, 2023b; <https://www.ftc.gov/system/files/ftc_gov/pdf/2022-Smokeless-Tobacco-Report.pdf>; accessed: February 22, 2024.
Jamal A, Park-Lee E, Birdsey J, West A, Cornelius M, Cooper MR, Cowan H, Wang J, Sawdey MD, Cullen KA, . Tobacco Product Use Among Middle and High School Students — National Youth Tobacco Survey, United States, 2024. Morbidity and Mortality Weekly Report 2024;73:917–924.39418216
Levy DT, Meza R, Yuan Z, Li Y, Cadham C, Sanchez-Romero LM, Travis N, Knoll M, Liber AC, Mistry R, . Public health impact of a U.S. ban on menthol in cigarettes and cigars: a simulation study. Tobacco Control 2023;32(e1):e37–e44.34475258
Shrestha SS, Ghimire R, Wang X, Trivers KF, Homa DM, Armour BS. Cost of cigarette smoking attributable productivity losses, U.S., 2018. American Journal of Preventive Medicine 2022; 63(4):478–85.35909028
Truth Initiative. Flavored tobacco policy restrictions as of September 30, 2023, 2023; <https://truthinitiative.org/sites/default/files/media/files/2024/01/Flavored-tobacco-policy-restrictions-Sept.30.2023.pdf>; accessed: February 22, 2024.
U.S. Department of Health and Human Services. Tobacco Use Among U.S. Racial/Ethnic Minority Groups—African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1998.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2012.
U.S. Department of Health and Human Services. The Health Consequences of Smoking—50 Years of Progress: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2014.
U.S. Department of Health and Human Services. HHS Framework to Support and Accelerate Smoking Cessation 2024, March 8, 2024; <https://www.hhs.gov/sites/default/files/hhs-frameworksupport-accelerate-smoking-cessation-2024.pdf>; accessed: April 17, 2024.
U.S. Department of Justice, Office of Public Affairs. Justice Department and FDA announce federal multi-agency task force to curb distribution and sale of illegal e-cigarettes [press release], June 10, 2024; <https://www.justice.gov/opa/pr/justice-department-and-fda-announce-federal-multi-agency-task-force-curb-distribution-and>; accessed: November 6, 2024.
U.S. Food and Drug Administration. FDA announces plans for proposed rule to reduce addictiveness of cigarettes and other combusted tobacco products: potential rule would propose to establish a maximum level of nicotine in cigarettes with the goal of reducing youth use, addiction and death [FDA news release], June 21, 2022; <https://www.fda.gov/news-eevents/pressannouncements/fda-announces-plans-proposed-rule-reduce-addictiveness-cigarettes-andother-combusted-tobacco>; accessed: May 22, 2023.