# Foreword

This decade, cigarette smoking among youth and adults reached the lowest levels ever recorded, representing a major public health milestone. Yet over 36 million U.S. adults (as of 2022) and 760,000 middle and high school students (as of 2024) smoke combustible tobacco products—including cigarettes, cigars, and other smoked products (Jamal et al. 2024; Centers for Disease Control and Prevention [CDC] 2024), and these products continue to have an enormous impact on health. E-cigarettes emerged in 2014 as the most commonly used tobacco product among U.S. youth and young adults and remain so in 2024, despite recent declines in use among high school students (Jamal et al. 2024). These and other noncombustible tobacco products such as nicotine pouches have the potential to undermine overall progress in preventing and reducing young people’s use of tobacco products.

This Surgeon General’s report documents the persistence of disparities in tobacco product use and exposure to secondhand tobacco smoke. As was true in the 1998 Surgeon General’s report—the first to exclusively examine racial and ethnic disparities in tobacco use—the present report finds that American Indian and Alaska Native people experience the highest prevalence of smoking of any racial and ethnic group. Even while overall youth tobacco product use declined between 2023 to 2024, use among American Indian and Alaska Native youth increased (Jamal et al. 2024). People who identify as lesbian, gay, bisexual, or transgender use tobacco products at substantially higher rates than those who identify as heterosexual or cisgender, respectively. Evidence in this report substantiates that menthol-flavored tobacco products increase the likelihood of tobacco initiation, addiction, and sustained use; are target marketed to certain population groups; and are disproportionately used by Black people, Native Hawaiian and Pacific Islander people, women, and people who identify as lesbian, gay, or bisexual. Disparities in exposure to secondhand tobacco smoke by race and by poverty level have persisted for at least three decades.

Preventing future generations from starting tobacco use and helping people quit is key to advancing the CDC’s mission to protect health and improve lives. Preventing and reducing tobacco use and tobacco-related health disparities not only reduces preventable death and disease caused by smoking but also enhances our protections against infectious disease and other disease risks. CDC engages in specific efforts to prevent and reduce tobacco use among groups disproportionately burdened by tobacco use through our expertise, response, and investments, including:

- Funding the National Tobacco Control Program (NTCP), which supports all 50 states, the District of Columbia, 28 tribes and tribal-serving organizations, and 8 territories and freely associated states. NTCP includes advancing health equity as one of four goals.
- Funding a consortium of national organizations (the National Networks) that works to reduce tobacco use and cancer incidence among minoritized racial and ethnic groups; people with lower socioeconomic status; people who identify as lesbian, gay, bisexual, transgender, queer or questioning, intersex, and other sexual orientation and gender identities (LGBTQI+); people with mental health conditions and substance use disorders; and various geographically defined populations. Operating since 1997, the National Networks consortium is the longest running federally funded initiative designed to address tobacco-related health disparities in diverse populations.
- Investing in the Good Health and Wellness in Indian Country (GHWIC) initiative that supports tribes, tribal organizations, and Tribal Epidemiology Centers across the United States through community-driven strategies to reduce tobacco use and other risk factors in tribal communities.
- Reaching people who smoke through Tips From Former Smokers (Tips), the first federally funded national tobacco education campaign. The campaign features real stories from real people living with serious long-term health effects from smoking and exposure to secondhand tobacco smoke. Tips advertisements have featured people from multiple population groups who experience tobacco-related health disparities and include specific placement designed to reach people who experience tobacco-related health disparities.
- Supporting culturally competent and free quitline services in every state, the District of Columbia, Guam, and Puerto Rico; in multiple languages; and with unique services or outreach to groups who are facing tobacco-related health disparities.
- Funding and supporting a $15 million initiative in 2023 to 8 communities to build a community of practice for state tobacco control programs and collaborators to develop and advance culturally competent interventions that (a) reduce initiation and use of menthol and other flavored tobacco products and (b) support and encourage sustained cessation among people who use menthol-flavored tobacco products.

CDC’s support to states and communities for tobacco prevention and cessation is a vital component to advancing health across all communities. This support serves as a foundational component of comprehensive efforts from USDHHS to prevent and reduce the harms of commercial tobacco use and their impact on other health conditions. Working in partnership across sectors, we must sustain and build upon these important efforts to prevent and reduce tobacco use and tobacco-related health disparities, measure collective progress, and be jointly accountable for results.

Mandy Cohen, M.D., M.P.H. Director Centers for Disease Control and Prevention