# Acknowledgments

This report was prepared by the U.S. Department of Health and Human Services under the general direction of the Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health.

Vice Admiral (VADM) Vivek H. Murthy, M.D., M.B.A., Surgeon General, Office of the Surgeon General, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Mandy K. Cohen, M.D., M.P.H., Director, Centers for Disease Control and Prevention, Atlanta, Georgia.

Karen Hacker, M.D., M.P.H., Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Peter A. Briss, M.D., M.P.H., Medical Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Rachel Kaufmann, Ph.D., M.P.H., Associate Director for Science, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Deirdre Lawrence Kittner, Ph.D., M.P.H., Director, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

## Editors of the report were

- Pebbles Fagan, Ph.D., M.P.H., Senior Scientific Editor, Professor, Department of Health Behavior and Health Education, Fay W. Boozman College of Public Health; Director, Center for the Study of Tobacco; Associate Director for Cancer Prevention and Control, Winthrop P. Rockefeller Cancer Institute; Director of Research, Office of Health Initiatives and Disparities Research, College of Medicine; University of Arkansas for Medical Sciences, Little Rock, Arkansas.
- Norval J. Hickman III, Ph.D., M.P.H., Senior Scientific Editor, Program Officer, Social Behavioral Sciences and Public Health, Tobacco-Related Disease Research Program, University of California, Office of the President, Oakland, California; Clinical Psychologist, The Wellness Within Psychotherapy and Consulting, PC, Oakland, California.
- Ryan Kennedy, Ph.D., Senior Scientific Editor, Associate Professor, Johns Hopkins Bloomberg School of Public Health, Johns Hopkins University, Baltimore, Maryland.
- Andrea Villanti, Ph.D., M.P.H., Senior Scientific Editor, Deputy Director, Rutgers Institute for Nicotine & Tobacco Studies, Rutgers Biomedical and Health Sciences; Associate Professor, Department of Health Behavior, Society, and Policy, Rutgers School of Public Health, New Brunswick, New Jersey.
- Brian A. King, Ph.D., M.P.H., Senior Associate Editor, Deputy Director for Research Translation, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Kristy L. Marynak, Ph.D., M.P.P., Senior Associate Editor, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Andrea S. Gentzke, Ph.D., M.S., Managing Editor, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Leslie A. Norman, M.B.A., Managing Editor, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Natasha Buchanan Lunsford, Ph.D., M.A., Contributing Editor, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Margaret A. Mahoney, J.D., Contributing Editor, Senior Public Health Analyst, Katmai Government Services (Contractor), Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Brenna VanFrank, M.D., M.S.P.H., Contributing Editor, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Peter L. Taylor, M.B.A., Technical Editor, Fairfax, Virginia.

## Contributing authors were

- Linda A. Alexander, Med., Ed.D., Senior Associate Dean and Professor, West Virginia University School of Public Health, Morgantown, West Virginia.
- Carla J. Berg, Ph.D., M.B.A., Professor, Department of Prevention & Community Health, Milken Institute School of Public Health; Associate Center Director for Population Sciences & Policy, George Washington Cancer Center; George Washington University, Washington, D.C.
- Micah Berman, J.D., Associate Professor, Health Services Management & Policy, College of Public Health & Moritz College of Law, The Ohio State University, Columbus, Ohio.
- Tess Boley Cruz, Ph.D., M.P.H., Associate Professor of Population and Public Health Sciences, University of Southern California, Los Angeles, California.
- Joanna E. Cohen, Ph.D., M.H.Sc., Director, Institute for Global Tobacco Control and Bloomberg Professor of Disease Prevention, Department of Health, Behavior, and Society, Johns Hopkins Bloomberg School of Public Health, Johns Hopkins University, Baltimore, Maryland.
- Daniel K. Crane-Hirsch, J.D., M.A., Senior Trial Attorney, Consumer Protection Branch, Civil Division, U.S. Department of Justice, Washington, D.C.
- Lauren M. Dutra, Sc.D., M.A., Research Scientist, Center for Health Analytics, Media, and Policy, RTI International, Berkeley, California.
- Sherry Emery, Ph.D., M.B.A., Senior Fellow in Public Health, Director of Social Data Collaboratory, NORC at the University of Chicago, Chicago, Illinois.
- Miao Feng, Ph.D., Research Scientist, NORC at the University of Chicago, Chicago, Illinois.
- Nancy L. Fleischer, Ph.D., M.P.H., Associate Professor, Department of Epidemiology, School of Public Health, University of Michigan, Ann Arbor, Michigan.
- Stanton Glantz, Ph.D., Professor of Medicine, Center for Tobacco Control Research and Education, University of California—San Francisco, San Francisco, California.
- Allison M. Glasser, Ph.D., M.P.H., Program Manager, Division of Health Behavior and Health Promotion, The Ohio State University College of Public Health, Columbus, Ohio.
- Mariaelena Gonzalez, Ph.D., Assistant Professor, School of Social Sciences, Humanities, and Arts, University of California—Merced, Merced, California.
- Rachel Grana Mayne, Ph.D., M.P.H., Program Director, Tobacco Control Research Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Kya Grooms, Ph.D., M.P.H., Oak Ridge Institute for Science and Education Fellow, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Mignonne C. Guy, Ph.D., Associate Professor and Chair, Department of African American Studies, Virginia Commonwealth University, Richmond, Virginia.
- Amy Y. Hafez, Ph.D., M.S., Postdoctoral Fellow, Center for Tobacco Control Research and Education, University of California—San Francisco, San Francisco, California.
- Bonnie Halpern-Felsher, Ph.D., Professor of Pediatrics, Division of Adolescent Medicine, Stanford University, Palo Alto, California.
- Laura Hamasaka, M.P.H., Independent Public Health Consultant, Washington, D.C.
- Lisa Anne Henriksen, Ph.D., Senior Research Scientist, Stanford Prevention Research Center, Department of Medicine, Stanford University School of Medicine, Palo Alto, California.
- David Homa, Ph.D., M.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Jidong Huang, Ph.D., Professor, Department of Health Policy & Behavioral Sciences, School of Public Health, Georgia State University, Atlanta, Georgia.
- Gary Humfleet, Ph.D., Professor, Department of Psychology, University of California—San Francisco, San Francisco, California.
- Jennifer Irvin Vidrine, Ph.D., Peggy and Charles Stephenson Endowed Chair in Cancer; Associate Director for Cancer Prevention and Control; Director of the Oklahoma Tobacco Research Center at the Stephenson Cancer Center; Professor, Department of Family and Preventive Medicine, University of Oklahoma Health Sciences; Oklahoma City, Oklahoma; Assistant Center Director for Research Community Partnerships, Moffitt Distinguished Scholar, and Senior Member, Department of Health Outcomes and Behavior and Office of Community Outreach, Engagement & Equity, Moffitt Cancer Center; Professor, Departments of Oncologic Sciences and Psychology, University of South Florida; Tampa, Florida.
- Sairam V. Jabba, D.V.M., Ph.D., Research Scientist, Department of Anesthesiology, Duke University School of Medicine, Durham, North Carolina.
- Jihyoun Jeon, Ph.D., M.S., Associate Research Scientist, Department of Epidemiology, University of Michigan, Ann Arbor, Michigan.
- Sven-Eric Jordt, Ph.D., Associate Professor of Anesthesiology and Pharmacology, Integrated Toxicology and Environmental Health Program, Duke University School of Medicine, Durham, North Carolina.
- Michelle C. Kegler, Dr.P.H., M.P.H., Director, Emory Prevention Research Center; Professor, Department of Behavioral, Social and Health Education Sciences, Rollins School of Public Health, Emory University, Atlanta, Georgia.
- Minji Kim, Ph.D., M.A., Postdoctoral Fellow, Center for Tobacco Control Research and Education, University of California—San Francisco, San Francisco, California.
- Jin E. Kim-Mozeleski, Ph.D., M.A., Assistant Professor, Department of Health Promotion and Policy, School of Public Health and Health Sciences, University of Massachusetts, Amherst, Massachusetts; Assistant Professor, Department of Population and Quantitative Health Sciences, Prevention Research Center for Healthy Neighborhoods, Case Western Reserve University, Cleveland, Ohio.
- Elizabeth G. Klein, Ph.D., M.P.H., Professor, Division of Health Behavior and Health Promotion, The Ohio State University College of Public Health, Columbus, Ohio.
- Anna Kostygina, Ph.D., Senior Research Scientist, Public Health Department, NORC at the University of Chicago, Chicago, Illinois.
- Margarete C. Kulik, Ph.D., Assistant Professor, Fay W. Boozman College of Public Health, University of Arkansas for Medical Sciences, Little Rock, Arkansas.
- Eric C. Leas, Ph.D., M.P.H., Assistant Professor, Herbert Wertheim School of Public Health, University of California—San Diego, La Jolla, California.
- Joseph G. L. Lee, Ph.D., M.P.H., Associate Professor, Department of Health Education and Promotion, College of Health and Human Performance, East Carolina University, Greenville, North Carolina.
- David T. Levy, Ph.D.; Professor, Lombardi Comprehensive Cancer Center, Georgetown University, Washington, D.C.
- Pamela Ling, M.D., M.P.H., Director, Center for Tobacco Control Research and Education; Professor, Department of Medicine, University of California—San Francisco, San Francisco, California.
- Jessica Liu, M.P.H., Population Health Sciences Doctoral Student, Department of Social and Behavioral Sciences, T.H. Chan School of Public Health, Harvard University, Cambridge, Massachusetts.
- Ann M. Malarcher, Ph.D., M.S.P.H., Senior Public Health Analyst, Katmai Government Services (Contractor), Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Wendy Max, Ph.D., Professor Emerita of Health Economics, Department of Social and Behavioral Sciences; Director Emerita, Institute for Health & Aging, School of Nursing, University of California—San Francisco, San Francisco, California.
- Tim McAfee, M.D., M.P.H., Professor (Adjunct), Department of Social and Behavioral Sciences, University of California—San Francisco; Associate Professor (Adjunct), Department of Health Systems and Population Health, School of Public Health, University of Washington; Senior Consultant, Plowshare Group, contracting with Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Rafael Meza, Ph.D., Professor, Department of Epidemiology, University of Michigan, Ann Arbor, Michigan.
- Sarah D. Mills, Ph.D., M.P.H., Assistant Professor, Department of Health Behavior, Gillings School of Global Public Health, University of North Carolina at Chapel Hill, Chapel Hill, North Carolina.
- Rebecca Murphy-Hoefer, Ph.D., M.P.H., Health Communications Specialist, Research, Evaluation, and Technical Assistance Team, Health Communications Branch, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Julianna M. Nemeth, Ph.D., M.A., Assistant Professor, Division of Health Behavior and Health Promotion, The Ohio State University College of Public Health, Columbus, Ohio.
- Nhung Nguyen, Ph.D., Postdoctoral Scholar, Center for Tobacco Control Research and Education, University of California—San Francisco, San Francisco, California.
- Cassandra Okechukwu, Sc.D., M.S.N., M.P.H., Principal Health and Life Scientist, Alliance to Modernize Healthcare (Federally Funded Research and Development Center), MITRE, Baltimore, Maryland.
- Pallav Pokhrel, Ph.D., M.P.H., Researcher (Professor), Population Sciences in the Pacific Program (Cancer Prevention in the Pacific), University of Hawai‘i Cancer Center, University of Hawai‘i at Mānoa, Honolulu, Hawaii.
- Amanda J. Quisenberry, Ph.D., M.S., Assistant Professor of Oncology, Assistant Member, Department of Health Behavior, Roswell Park Comprehensive Cancer Center, Buffalo, New York.
- Kurt M. Ribisl, Ph.D., Jo Anne Earp Distinguished Professor and Chair, Department of Health Behavior, UNC Gillings School of Global Public Health, Chapel Hill, North Carolina.
- Megan E. Roberts, Ph.D., Associate Professor, Division of Health Behavior and Health Promotion, The Ohio State University College of Public Health, Columbus, Ohio.
- April Roeseler, M.S.P.H., B.S.N., Chief, California Tobacco Control Program, Center for Healthy Communities, California Department of Public Health, Sacramento, California.
- Shyanika W. Rose, Ph.D., M.A., Assistant Professor, Department of Behavioral Science and Center for Health Equity Transformation, College of Medicine, University of Kentucky, Lexington, Kentucky.
- Leslie Ross, M.P.H., C.H.E.S., Health Scientist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Glorian Sorensen, Ph.D., M.P.H., Professor of Social and Behavioral Sciences, Harvard T.H. Chan School of Public Health and Dana-Farber Cancer Institute, Boston, Massachusetts.
- Hai-Yen Sung, Ph.D., Professor of Health Economics, Institute for Health & Aging, University of California—San Francisco, San Francisco, California.
- Steve Sussman, Ph.D., F.A.A.H.B., F.A.P.A., F.S.P.R., Professor of Population and Public Health Sciences, Psychology, and Social Work, University of Southern California, Los Angeles, California.
- Jamie Tam, Ph.D., M.P.H., Assistant Professor, Department of Health Policy and Management, Yale School of Public Health, New Haven, Connecticut.
- Andy S. L. Tan, Ph.D., M.P.H., M.B.A., M.B.B.S., Assistant Professor, Dana-Farber Cancer Institute, Division of Population Sciences, Center for Community-Based Research; Assistant Professor, Harvard TH Chan School of Public Health, Department of Social and Behavioral Sciences, Boston, Massachusetts.
- Sonia Tetlow, Ph.D., M.P.H., Health Scientist, Division of Global Health Protection, Center for Global Health, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Hilary Tindle, M.D., M.P.H., Founding Director of ViTAL (Vanderbilt Center for Tobacco, Addiction, and Lifestyle); Associate Professor of Medicine and the William Anderson Spickard, Jr. M.D. Chair in Medicine, Division of General Internal Medicine and Public Health, Vanderbilt University Medical Center and Vanderbilt-Ingram Cancer Center, Nashville, Tennessee.
- Dennis R. Trinidad, Ph.D., M.P.H., Professor, Division of Health Policy, Department of Family Medicine and Public Health, School of Medicine, University of California—San Diego, La Jolla, California.
- James Tsai, M.D., M.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Janice Y. Tsoh, Ph.D., Professor, Department of Psychiatry and Behavioral Sciences, University of California—San Francisco, San Francisco, California.
- Michael A. Tynan, M.P.H., Public Health Analyst, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Jennifer B. Unger, Ph.D., Professor of Population and Public Health Sciences, University of Southern California, Los Angeles, California.
- Damon J. Vidrine, Dr.P.H., M.S., Program Leader for Cancer Prevention and Control at the Stephenson Cancer Center; Professor, Department of Family and Preventive Medicine, University of Oklahoma Health Sciences, Oklahoma City, Oklahoma; Chair, Distinguished Scholar and Senior Member, Department of Health Outcomes and Behavior, Moffitt Cancer Center; Professor, Morsani College of Medicine, University of South Florida, Tampa, Florida.
- Nicole (CoCo) Villaluz, B.A., Deputy Director, American Indian Cancer Foundation, Minneapolis, Minnesota; Consultant, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Maya Vijayaraghavan, M.D., M.A.S., Associate Professor of Medicine, University of California—San Francisco, San Francisco, California.
- Monica Webb Hooper, Ph.D., Associate Director, Cancer Disparities Research; Director, Office of Cancer Disparities Research, Case Comprehensive Cancer Center; Professor of Oncology, Psychological Sciences, and Family Medicine and Community Health, Case Western Reserve University, Cleveland, Ohio.
- Tingting Yao, Ph.D., Assistant Professor, University of California—San Francisco, San Francisco, California.
- Thomas Ylioja, Ph.D., M.S.W., Clinical Director, Health Initiatives; Assistant Professor, Division of Pulmonary, Critical Care, and Sleep Medicine, National Jewish Health, Denver, Colorado.

## Reviewers were

- Brian Armour, Ph.D., Associate Director for Science, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Rene Arrazola, M.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Euna August, Ph.D., M.P.H., M.C.H.E.S., Deputy Associate Director for Science, Office of Health Equity, Office of the Director, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Sunday Azagba, Ph.D., M.S., M.A., Associate Professor, Division of Public Health, Department of Family and Preventive Medicine, University of Utah School of Medicine, Salt Lake City, Utah.
- Tonatiuh Barrientos-Gutierrez, M.D., Ph.D., Director, Center for Population Health Research, National Institute of Public Health, Cuernavaca, Morelos, Mexico.
- Diane Beistle, B.A., Branch Chief, Health Communications Branch, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Michele Bloch, M.D., Ph.D., Chief, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Peter A. Briss, M.D., M.P.H., Medical Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Natasha Buchanan Lunsford, Ph.D., M.A., Associate Director for Health Equity, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Priscilla Callahan-Lyon, M.D., Senior Science Advisor, Office of the Center Director, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Yessenia Castro, Ph.D., Associate Professor and Associate Dean for Doctoral Education, Steve Hicks School of Social Work, The University of Texas, Austin, Texas.
- Won S. Choi, Ph.D., M.P.H., Professor, Department of Population Health, University of Kansas Medical Center, Kansas City, Kansas.
- Joanna E. Cohen, Ph.D., M.H.Sc., Director, Institute for Global Tobacco Control and Bloomberg Professor of Disease Prevention, Department of Health, Behavior, and Society, Johns Hopkins Bloomberg School of Public Health, Johns Hopkins University, Baltimore, Maryland.
- Elizabeth Courtney-Long, M.A., M.S.P.H., Deputy Associate Director for Science, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Daniel K. Crane-Hirsch, J.D., M.A., Senior Trial Attorney, Consumer Protection Branch, Civil Division, U.S. Department of Justice Department, Washington, D.C.
- MeLisa R. Creamer, Ph.D., M.P.H., Deputy Branch Chief, Epidemiology Research Branch, Division of Epidemiology, Services, and Prevention Research, National Institute on Drug Abuse, Bethesda, Maryland.
- K. Michael Cummings, Ph.D., M.P.H., Professor, Department of Psychiatry and Behavioral Sciences, Medical University of South Carolina, Charleston, South Carolina.
- Paula Cupertino, Ph.D., Associate Director, Community Outreach, Engagement, and Disparities, Department of Public Health Sciences, Wilmot Cancer Institute, University of Rochester Medical Center, Rochester, New York.
- M. Imad Damaj, Ph.D., Professor, Department of Pharmacology and Toxicology, Virginia Commonwealth University, Richmond, Virginia.
- Cristine Delnevo, Ph.D., M.P.H., Director, Rutgers Institute for Nicotine & Tobacco Studies; Professor, Department of Health Behavior, Society, and Policy, Rutgers School of Public Health, New Brunswick, New Jersey.
- W. Douglas Evans, Ph.D., Professor of Prevention and Community Health and Global Health; Director, Behavioral Research Insights and diGital Health Technology (BRIGHT) Institute, Milken Institute School of Public Health, The George Washington University, Washington, D.C.
- Eric (Rocky) Feuer, Ph.D., Branch Chief, Statistical Research and Applications Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Neal Freedman, Ph.D., M.P.H., Chief, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Kathryn Gallagher, Associate Director for Policy, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Gary A. Giovino, Ph.D., M.S., The State University of New York (SUNY) Distinguished Professor Emeritus, School of Public Health and Health Professions, University at Buffalo, SUNY, Buffalo, New York.
- Thomas J. Glynn, Ph.D., M.S., M.A., Adjunct Lecturer, Prevention Research Center, School of Medicine, Stanford University, Palo Alto, California.
- Meredith Grady, M.P.H., Tobacco Control Research Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Rachel Grana Mayne, Ph.D., M.P.H., Program Director, Tobacco Control Research Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Ellen J. Hahn, Ph.D., R.N., FAAN, Director, Bridging Research Efforts and Advocacy Toward Healthy Environments (BREATHE); Professor, College of Nursing, University of Kentucky, Lexington, Kentucky.
- Brandon J. Henderson, Ph.D., Co-Chair, Basic Science Network, Society for Research on Nicotine and Tobacco; Assistant Professor, Department of Biomedical Sciences, Joan C. Edwards School of Medicine at Marshall University, Huntington, West Virginia.
- Nadia Howlader, Ph.D., Program Director, Data Analytics Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Corinne G. Husten, M.D., M.P.H., Senior Medical Advisor, Office of the Center Director, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland; Medical Officer, Katmai Government Services (Contractor), Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Annette Kaufman, Ph.D., M.P.H., Program Director, Tobacco Control Research Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Joseph Keawe‘aimoku Kaholokula, Ph.D., Professor and Chair, John A. Burns School of Medicine, Department of Native Hawaiian Health, University of Hawai‘i at Mānoa, Honolulu, Hawaii.
- Gary King, Ph.D., Professor of Biobehavioral Health, College of Health and Human Development, Pennsylvania State University, State College, Pennsylvania.
- Thomas R. Kirchner, Ph.D., M.S., Assistant Professor, Department of Social and Behavioral Sciences, School of Global Public Health, New York University, New York, New York.
- Deirdre Lawrence Kittner, Ph.D., M.P.H., Director, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- William Klein, Ph.D., Associate Director, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Stephanie Land, Ph.D., Program Director, Tobacco Control Research Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Margaret Mayer, Ph.D., M.P.H., Program Director, Tobacco Control Research Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Candace Maynard, M.P.A., Office of Program Management, Office of Communications and Public Liaison, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Tim McAfee, M.D., M.P.H., Professor (Adjunct), Department of Social and Behavioral Sciences, University of California—San Francisco; Associate Professor (Adjunct), Department of Health Systems and Population Health, School of Public Health, University of Washington; Senior Consultant, Plowshare Group, contracting with Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Robin Mermelstein, Ph.D., Distinguished Professor, Psychology Department; Director, Institute for Health Research and Policy, University of Illinois, Chicago, Illinois.
- Linda Neff, Ph.D., Branch Chief, Epidemiology Branch, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Patricia Nez Henderson, M.D., M.P.H., Senior Scientist, Black Hills Center for American Indian Health, Rapid City, South Dakota.
- Kola Okuyemi, M.D., M.P.H., Professor and Department Chair, The George D. Gross, M.D., and Esther M. Gross, M.D., Presidential Endowed Chair in Family and Preventive Medicine, Department of Family and Preventive Medicine, University of Utah School of Medicine, Salt Lake City, Utah.
- Mark Parascandola, Ph.D., M.P.H., Branch Director, Research and Training Branch, Center for Global Health, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Ana Penman-Aguilar, Ph.D., M.P.H., Chief Science Officer and Associate Director for Science, Office of Health Equity, Office of the Director, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Yvonne Prutzman, Ph.D., M.P.H., Program Director, Tobacco Control Research Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Kakoli Roy, M.A., Ph.D., Senior Economic Advisor, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Jonathan M. Samet, M.D., M.S., Dean and Professor, Colorado School of Public Health, University of Colorado, Aurora, Colorado.
- Lisa Sanderson Cox, Ph.D., Professor, Department of Population Health, University of Kansas School of Medicine, Kansas City, Kansas.
- Gillian L. Schauer, Ph.D., M.P.H., Research Scientist, Addictions, Drug, and Alcohol Institute, Department of Psychiatry and Behavioral Sciences, School of Medicine, University of Washington, Seattle, Washington.
- Adrian Shanker, Office of the Assistance Secretary of Health, U.S. Department of Health and Human Services, Washington, D.C.
- Jean Shapiro, Ph.D., Health Scientist, Office of Medicine and Science, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Saida Sharapova, M.D., M.P.H., C.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Karla S. Sneegas, M.P.H., Branch Chief, Program Services Branch, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Anna Song, Ph.D., Associate Professor of Health Psychology; Director, University of California Merced Nicotine and Cannabis Policy Center, Health Sciences Research Institute, University of California—Merced, Merced, California.
- Anne L. Sowell, Ph.D., Health Scientist, Office of Medicine and Science, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Stephen B. Stanfill, M.S., Research Chemist, Tobacco and Volatiles Branch, Division of Laboratory Sciences, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.
- James F. Thrasher, Ph.D., M.S., M.A., Professor, Department of Health Promotion, Education and Behavior, Arnold School of Public Health, University of South Carolina, Columbia, South Carolina.
- Elisa Tong, M.D., M.A., Professor, Division of General Internal Medicine, University of California—Davis, Davis, California.
- Katrina F. Trivers, Ph.D., M.S.P.H., Lead Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Christina V. Watson, Dr.P.H., M.P.H., Health Scientist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Clifford H. Watson, Ph.D., Lead Research Chemist, Tobacco and Volatiles Branch, Division of Laboratory Sciences, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.

## Other contributors were

- Fatma Romeh Ali, Ph.D., Fellow, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Rene Arrazola, M.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Aja Arrindell, Data Analyst, Veritas Management Group, Atlanta, Georgia.
- Katherine J. Asman, M.S.P.H., Statistician, Biostatistics and Epidemiology Division, RTI International, Atlanta, Georgia.
- Monica Cornelius, Ph.D., Health Scientist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- MeLisa R. Creamer, Ph.D., M.P.H., Oak Ridge Institute for Science and Education Fellow, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Amy de Boinville, Production Design Associate, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Kalle Diarra, Director, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Carolyn Feola, Production Design Specialist, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Ellen Galstyan, Doctoral Student, Department of Population and Public Health Sciences, Keck School of Medicine, University of Southern California, Los Angeles, California.
- Ollie Ganz, Dr.P.H., M.S.P.H., Assistant Professor, Department of Health Behavior, Society and Policy, Rutgers School of Public Health; Core Faculty, Rutgers Institute for Nicotine & Tobacco Studies, Rutgers Biomedical and Health Sciences, New Brunswick, New Jersey.
- Jeane Garcia Davis, M.S.N./M.P.H., R.N., Office of the Surgeon General, U.S. Department of Health and Human Services, Washington, D.C.
- Phillip Gardiner, Dr.P.H., Senior Program Officer, Tobacco-Related Disease Research Program, University of California, Office of the President, Oakland, California; Co-Chair, African American Tobacco Control Leadership Council, San Francisco, California.
- Jane Garwood, Senior Editor, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Andrea S. Gentzke, Ph.D., M.S., Health Scientist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Sondra Hammond, Production Design Associate, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Onelia Hawa, B.A., Oak Ridge Institute for Science and Education Fellow, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Allison Hoffman, Ph.D., M.A., Deputy Director for Research Translation, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Sean Hu, M.D., M.S., Dr.P.H., Senior Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Corinne G. Husten, M.D., M.P.H., Senior Medical Advisor, Office of the Center Director, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland; Medical Officer, Katmai Government Services (Contractor), Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Ebony Jackson Griffin, M.P.H., Associate Director of Health Equity, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Ahmed Jamal, M.D., M.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Daniel Kagwisa, Data and Analytics Engineer, Veritas Management Group, Atlanta, Georgia.
- Nichole M. Kagwisa, Project Manager, Veritas Management Group, Atlanta, Georgia.
- Devon LaPoint, Project Director, American Institutes for Research, Arlington, Virginia.
- Melanie LaVake, B.S., Research Teaching Specialist, Rutgers Institute for Nicotine & Tobacco Studies, Rutgers Biomedical and Health Sciences, New Brunswick, New Jersey.
- Dara Ledford, Senior Manager, AIR Studio, American Institutes for Research, Arlington, VA.
- Pamela Lemos, M.S., Public Health Analyst, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Rod Lew, M.P.H., Executive Director, Asian Pacific Partners for Empowerment, Advocacy, and Leadership, Oakland, California.
- Caitlin G. Loretan, M.P.H., Health Scientist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Luis Martinez, Graphic Design Specialist, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Martha Mater, Senior Manager, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Deborah McLellan, Ph.D., M.H.S., Senior Scientist, Dana-Farber Cancer Institute, Boston, Massachusetts; Harvard T.H. Chan School of Public Health, Boston, Massachusetts.
- Matthew Mowczko, M.Des., Graphic Design Specialist, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Atul Nakhasi, M.D., M.P.P., Office of the Surgeon General, U.S. Department of Health and Human Services, Washington, D.C.
- Stephanie Neuben, Editor, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Lori New Breast, B.A., Blackfeet Tribe Member Consultant; Consultant, Mahnokini & Associates, Blackfeet Indian Reservation, Montana.
- Jeannette Noltenius, Ph.D., M.A., Health Equity Advocate, Washington, D.C.
- Jeanette (J’ette) Novakovich, Ph.D., Writer-Editor, Office on Smoking and Health, National Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Wato Nsa, Data Analyst, Veritas Management Group, Atlanta, Georgia.
- Kim O’Brien, Editor, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Andrew Peterman, Lead Production Editor, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Robert Proctor, Ph.D., M.S., Professor of the History of Science, School of Humanities and Sciences, Stanford University, Stanford, California.
- Amy Rosenstein, Editor, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Scout, Ph.D., M.A., Deputy Director, The National LGBT Cancer Network, Providence, Rhode Island.
- Saida Sharapova, M.D., M.P.H., C.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Sundar Shrestha, Ph.D., Senior Economist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Stephen Stanfill, M.S., Research Chemist, Tobacco and Volatiles Branch, Division of Laboratory Sciences, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Girija Syamlal, M.B.B.S., M.P.H., Epidemiologist, Division of Respiratory Disease Surveillance, National Institute for Safety and Health, Centers for Disease Control and Prevention, Morgantown, West Virginia.
- Kathryn Szynal, Health Researcher, Chenega Enterprise Systems and Solutions, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Stacy Thorne, Ph.D., M.P.H., Health Scientist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Andrea Titus, M.P.P., Graduate Student Research Assistant, Division of Epidemiology, School of Public Health, University of Michigan, Ann Arbor, Michigan.
- Randi Tolstyk, M.S.Ed., Public Health Analyst, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- James Tsai, M.D., M.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Donna Vallone, Ph.D., M.P.H., Chief Research Officer, Truth Initiative; Adjunct Associate Professor, New York University, New York, New York.
- Nishika A. Vidanage-Lulejian, M.P.H., M.A., Program Analyst, Katmai Government Services (Contractor), Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Sharon Wallace, Production Design Specialist, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Kimp Walton, M.S., Health Statistician, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Teresa Wang, Ph.D., M.S., Epidemic Intelligence Service Officer, Lieutenant, U.S. Public Health Service, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Karen Ward, Production Design Specialist, AIR Studio, American Institutes for Research, Arlington, Virginia.
- Christina V. Watson, Dr.P.H., M.P.H., Health Scientist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Clifford H. Watson, Ph.D., Lead Research Chemist, Tobacco and Volatiles Branch, Division of Laboratory Sciences, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Kevin Whelan, Project Manager, American Institutes for Research, Arlington, Virginia.
- Lindsey Willis, P.M.P., Project Director (Former), American Institutes for Research, Arlington, Virginia.
- Lei Zhang, Ph.D., Health Scientist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.