# Message from Xavier Becerra, Secretary, U.S. Department of Health and Human Services

Twenty-five years after the release in 1998 of the first Surgeon General’s report to focus specifically on racial and ethnic disparities in commercial tobacco use, we have made substantial progress in reducing tobacco use at the population level. However, many disparities in the use of tobacco products continue to be observed by race and ethnicity, level of income, level of education, sexual orientation and gender identity, occupation, geography, behavioral health status, and disability status.

Everyone deserves to live a healthy life free from commercial tobacco-related disease and pre-mature death. Using a multidisciplinary perspective, this Surgeon General’s report reviews the latest scientific evidence about drivers of tobacco-related health disparities and interventions to prevent and reduce them. It concludes with a bold vision to advance tobacco-related health equity.

At the federal level, pivotal steps are being taken to advance public health across the whole population through both regulatory and administrative actions, including actions that will also promote tobacco-related health equity. The U.S. Food and Drug Administration (FDA) has announced that it intends to advance a product standard that would establish a maximum nicotine yield to reduce the addictiveness of cigarettes and certain other combusted tobacco products to minimally addictive or nonaddictive levels (Federal Register 2018; FDA 2022). This action would have significant impact on public health if promulgated. Additionally, the FDA has proposed product standards to prohibit menthol as a characterizing flavor in cigarettes and prohibit characterizing flavors (except tobacco) in cigars (Federal Register 2022a,b)—actions with strong potential to benefit public health.

Many people who now use commercial tobacco products have the least resources for, and face the greatest barriers to, quitting. It is critical to couple any regulatory efforts to reduce the appeal and addictiveness of commercial tobacco products with evidence-based, accessible support to help people quit their use of these products. To advance this goal, the U.S. Department of Health and Human Services (USDHHS) released the USDHHS Framework to Support and Accelerate Smoking Cessation (USDHHS 2024). This framework provides direction to enhance collaboration and coordination across USDHHS, drive further progress toward smoking cessation, and ensure equitable outcomes for all persons in America.

In addition to these critical efforts to address the use of combusted tobacco products—which are responsible for the overwhelming burden of tobacco-related death and disease in the United States—additional efforts are also underway to prevent and reduce youth access to and use of all tobacco products, including e-cigarettes. In June 2024, the Justice Department and FDA announced the creation of a federal multi-agency task force to combat the illegal distribution and sale of e-cigarettes (U.S. Department of Justice 2024). This report underscores the importance of such actions to curb harmful industry tactics, documenting how tobacco companies, including e-cigarette manufacturers, have attempted to circumvent national, state, and local tobacco prevention and control policies—such as by introducing products containing synthetic nicotine—and to use litigation to challenge policies proven to benefit the public’s health.

Taken together, these initiatives are expected to meaningfully advance efforts to eliminate the burden of death and disease caused by commercial tobacco use. But to be successful, we must engage all sectors of society. Now is the time to close the gap in tobacco-related health disparities in the United States—for everyone.