# Chapter 8 A Vision for Eliminating Commercial Tobacco-Related Health Disparities

## Introduction

The 50th anniversary Surgeon General’s report published in 2014 posed the question, “As future generations look back on our current actions and knowledge of the tobacco epidemic, will current efforts show the commitment to public health and social justice set forth in our national plans and objectives?” (U.S. Department of Health and Human Services [USDHHS] 2014, p. 875). The present chapter establishes a vision and call to action for all to commit to advancing tobacco-related health equity. Supporting communities disproportionately burdened by commercial tobacco use and exposure involves (1) acknowledging the historical context of tobacco-related health disparities; (2) removing the underlying causes of tobacco-related health disparities, including structural racism and discrimination and other social and structural factors that influence this burden; (3) ensuring that populations subject to targeted marketing by commercial tobacco companies and to tobacco-related health disparities are not blamed for these disparities or burdened with the responsibility to ameliorate them; and (4) undertaking a “both/and” approach to addressing tobacco-related disparities by advancing tobacco-specific interventions and social and structural interventions. This chapter begins by reflecting on the past, present, and future of tobacco-related health disparities. It concludes with a vision for advancing tobacco-related health equity and removing structural barriers that perpetuate disparities, while simultaneously advancing population health with the goal of eliminating tobacco-related morbidity and mortality (Robeznieks 2019; Barber 2020).

The 2014 Surgeon General’s report concluded that, “Although cigarette smoking has declined significantly since 1964, very large disparities in tobacco use remain across groups defined by race, ethnicity, educational level, and socioeconomic status and across regions of the country” (USDHHS 2014, p. 7). These disparities persist today. The present report expands the scope of tobacco-related health disparities to include self-reported sexual orientation and gender identity, intersectionality, and other factors. Nationally representative data described in this Surgeon General’s report show that

- The prevalence of current (past-month) cigarette smoking in 2019 was highest among aggregate groups of American Indian and Alaska Native adults (30.7%) and adults who identified as non-Hispanic, multi-race (30.6%), followed by Black (20.6%), White (19.4%), Native Hawaiian and Pacific Islander (14.1%), Hispanic (13.4%), and Asian (8.0%) adults.
- Among youth, the prevalence of current cigarette smoking in 2019 was highest among aggregate groups of American Indian and Alaska Native youth (20.6%), followed by youth who identified as non-Hispanic, multi-race (8.0%), White (6.7%), Hispanic (6.0%), Native Hawaiian and Other Pacific Islander (4.5%), Black (3.3%), and Asian (2.3%).
- Among adults who smoked during 2017–2019, menthol cigarette use was highest among Black or African American people (88.1%), followed by Native Hawaiian and Pacific Islander (73.5%), Multi-Race (48.7%), Hispanic or Latino (47.3%), Asian (43.6%), American Indian and Alaska Native (32.2%), and White (28.9%) people.
- The prevalence of cigarette smoking is nearly twice as high among lesbian, gay, and bisexual youth as it is among heterosexual youth.
- Disparities in cigarette smoking by level of income have persisted over four decades, with smoking prevalence higher among people living below the federal poverty level.
- Despite substantial overall progress in reducing exposure to secondhand tobacco smoke at the population level, protections have not been equitable across racial and ethnic groups, socioeconomic groups, or by age. From about 1988 to 2018, absolute disparities in exposure to secondhand tobacco smoke increased among children compared to adults, among Black or African American people compared to White and Hispanic people, and among people living below the poverty line compared to people living above the poverty line.
- Disparities in the use of evidence-based cessation treatments exist, including among population groups defined by race and ethnicity, socioeconomic status, and health insurance coverage status.

## An Ethical Foundation for Addressing Tobacco-Related Health Disparities

This report frames inequitable policies, practices, and socially determined conditions as contributors to tobacco-related health disparities and uses the theory of social justice emerging from the field of bioethics as an ethical foundation for addressing these contributors. This approach recognizes that such indicators as the prevalence of tobacco product use, smoking-attributable mortality, exposure to secondhand tobacco smoke, and having received advice from a health professional to quit tobacco use also occur within the context of social and economic circumstances, including the marketing, distribution, and sale of commercial tobacco products. Drivers of tobacco-related health disparities include social and structural determinants of health—such as persistent poverty and inequitable economic and social conditions—that lead to inequitable opportunities for health. Discrimination, racism, and targeted marketing by the tobacco industry; geographic disparities in comprehensive smokefree policies; preemptive laws that hinder political empowerment to protect the health and safety of communities; and financial and other structural barriers to accessing cessation treatments also drive health disparities. These drivers have cumulative effects across the lifespan and diminish the general welfare of the nation.

The theory of social justice, as presented by bioethicists Powers and Faden (2006, 2019), is centrally concerned with the achievement of human well-being, which includes but is not limited to physical and mental health. Additional dimensions of well-being include personal security, knowledge and understanding, equal respect, personal attachments (i.e., through interpersonal bonds), and self-determination. Population groups that fare poorly on multiple dimensions, Powers and Faden (2006, p. 15) noted, should be prioritized with “special moral urgency.” The “job” of social justice is to identify patterns of disadvantage that result in the systematic marginalization of groups (Powers and Faden, 2006, p. 3), including tobacco-related health disparities.

Previous chapters examined the interlocking factors that influence tobacco-related health disparities. As represented in Figure 1.1 in Chapter 1 of this report, historical context, differential power structures, and the ideology and values of those with decision-making authority influence (a) commercial drivers of tobacco product use and exposure (including marketing tactics) and (b) economic and political systems, institutions, policies, and research and interventions that establish the context for health and well-being. Industry tactics—including marketing, product design, lobbying, and corporate social responsibility initiatives (Kickbusch et al. 2016)—reflect and reinforce existing structural inequities, racism and discrimination, poverty, historical and present-day trauma, and other stressors that perpetuate health disparities. These converging social and commercial determinants of health predispose, enable, and reinforce differential opportunities to live a life free of premature death and disease caused by commercial tobacco product use and exposure to secondhand tobacco smoke.

The pursuit of social justice in public health does not benefit only those who have been subject to systematic and cumulative disadvantage. Everyone is harmed by inequity, and everyone can benefit from equity. This is observable within and outside the context of tobacco control, for example,

- Equitable smokefree protections promote health, reduce healthcare costs borne by society, and do not harm businesses (Centers for Disease Control and Prevention [CDC] 2021c).
- Models from the Center for Medicare & Medicaid Innovation increasingly address health-related social needs. The Accountable Health Communities model, on which these efforts are built, showed patterns of reduced avoidable and overall emergency room use among Medicare beneficiaries by connecting them to housing, food, and other services. These impacts were more pronounced among Medicare beneficiaries who are Hispanic or a race other than White (Centers for Medicare & Medicaid Services 2023, n.d.).
- Multisector, place-based initiatives, with active participation of community residents, can reinvest in high-need neighborhoods (Dankwa-Mullan and Pérez-Stable 2016). Such initiatives have been shown to increase employment and graduation rates among families with lower incomes, reduce crime, and raise property values in the surrounding area (Bailey et al. 2017; Purpose Built Communities n.d.).

To guide future directions, it is important to acknowledge and learn from the past and present. The following sections discuss the past, present, and future of tobacco-related health disparities in the United States and offer a vision for advancing tobacco-related health equity—with fair and just opportunities and conditions for all people to live a healthy life that is free from tobacco use and exposure and from tobacco-related disease, disability, and death.

### Past: A Complex History of Tobacco Commercialization and the Involvement of the Tobacco Industry in Communities

Addressing tobacco-related health disparities requires a reflection on the complex history of the commercialization of tobacco. Chapter 1 summarized how some American Indian communities’ ceremonial or traditional tobacco was repurposed during the colonial period into a commercial crop, and it documented how federal policies separated Indigenous communities from their lands and effectively prohibited ceremonial uses of tobacco while allowing the use of commercial tobacco. Chapter 1 further documented the historical ties between cultivation of tobacco for commercial purposes and the enslavement of people of African descent. This historical context is a foundational driver of present-day socioeconomic and health disparities.

The 1998 Surgeon General’s report (USDHHS 1998) documented the industry’s targeting of racial and ethnic communities through direct employment, support for social services and civil rights organizations, contributions to politicians and political organizations, support for educational and cultural programs, and contracts with small businesses. Tobacco industry documents reveal that the intent of these community engagement efforts is to drive sales of tobacco products among the very groups the companies purport to help (Table 8.1). As determinants of tobacco-related health disparities, these tactics persist and affect additional and intersectional population groups, including people who are lesbian, gay, bisexual, transgender, queer, intersex, or other sexual orientation and gender identities (LGBTQI+).

Table 8.1 Present-day and historic examples of targeted community engagement tactics outlined in industry documents

Tactic | Historic examples from tobacco industry documents | Present-day examples
Indirect/grassroots lobbying and advocacy to encourage the general electorate to oppose tobacco control measures, such as menthol restrictions and cigarette tax ballot initiatives | “Since it is apparent that we are not going to have the endorsement of most Gay and Lesbian leadership, it is important to use these campaign tools to bypass that and go directly to the Gay and Lesbian voter with a message that will resonate … [A]reas that would have special interest to this community … include lifestyle regulation, government intrusion into private lives, and removing choice as an option for one’s life decisions” (Mixner 1998, p. 5). | - 2022: Direct-to-consumer emails from R.J. Reynolds-affiliated cigarette (Natural American Spirit) and smokeless tobacco (Grizzly) brands called on consumers to take action to oppose menthol bans (PennRutgers TCORS 2022). A Philip Morris (Marlboro) email stated, “These flavor bans can create underground markets that increase crime, reduce tax revenues and hurt small businesses” (Trinkets & Trash 2022).; - 2021: Email from Natural American Spirit in July 2021 urged recipients to say “no” to more cigarette taxes (Trinkets & Trash 2021).
Targeted marketing and segregated marketing | “Reynolds Tobacco has made a special effort to reach Black smokers since the early 1960s [and] special efforts for Hispanics since the early 70s” (Winebrenner 1988, p. 2).; “Any attempt to cater to blacks could backfire and hurt Marlboro among the young blue collar whites who constitute the Marlboro franchise” (Johnston 1982, p. 5). | - 2022: Digital images from Kool non-menthol brand cigarettes featured African- American men and women smoking and included such text as, “By now, you may have heard that California has banned menthol cigarettes. If you’re like, ‘what now?!’ We got you. Discover Kool Non-Menthol. Same Intensity. Same Vibe. Minus the Menthol” (Stanford Research into the Impact of Tobacco Advertising n.d.).; - 2019: Direct-to-consumer email encouraged recipients to “explore the Latinx hip-hop movement and earn points for Marlboro Rewards” (Trinkets & Trash 2019).
Support for social services and civil rights organizations | “Association with a national civil rights organization can be viewed, in its most positive sense, as an endorsement of Brown & Williamson and its products to the minority community…. Clearly, the sole reason for B&W’s interest in the black and Hispanic communities is the actual and potential sales of B&W products within these communities and the profitability of these sales” (MAB 1984, p. 1). | - 2022: Altria reported its 2020 charitable contributions to civil rights and social services organizations (Altria n.d.).; - 2020: An Instagram post from Imperial Brands’ subsidiary Dutch Masters Cigar and Cigarillo said “Black Lives Matter” (Figure 2 in Heley et al. 2021).
Contributions to politicians, political organizations, and lobbying groups | “We cannot view politics as a spectator sport. The most effective way we can work together to help our Company participate is to become a member of the RJR Political Action Committee. … By combining our contributions, we speak with a united, powerful voice. We help elect legislators who support business interests. In doing so, we help build a stronger future for ourselves and our co-workers…Contributing to the PAC ensures we have a voice in helping shape the debate before laws and regulations are passed” (Schindler 2000, p. 1). | - 2022: Altria reported its 2020 charitable contributions to high-profile political organizations, Congressional caucuses that advocate on behalf of people from minoritized racial and ethnic groups, and lobbying groups that oppose taxes or promote tobacco harm reduction (Altria n.d.).; - 2022: “Reynolds American Companies reported political contributions totaling US $6,229,475 for the full year 2020 to US political organisations and to non-federal-level political party and candidate committees” (British American Tobacco 2021, p. 116).
Support for educational and cultural programs | “Tie-in with any company who help black—‘we help them, they help us.’ Target group age 16+” (Davis 1978, p. 8). “Four leading Black publishers from the National Newspaper Publishers Association will visit with us … [Areas for discussion include:]; - How the Black Press can support the Tobacco Industry in the smoking-health controversy; - General advertising; - R.J. Reynolds Industries—NNPA Scholarship Program in Journalism” (Sticht 1979). | - 2022: Altria reported that charitable contributions in 2020 went to scholarship funds for Black and Hispanic youth, youth-serving organizations, and numerous colleges and universities (Altria n.d.).; - 2022: Santa Fe Natural Tobacco Company Foundation (Reynolds American) “is dedicated to helping preserve, promote, and advance American Indian Culture. Using dedicated funds from the sale of SFNTC tobacco products, the Foundation’s three primary objectives are: development of Native American entrepreneurs; facilitation of Native American education; and preservation of Native American languages” (Reynolds American n.d.).
Hire members of minoritized communities for public-facing and advocacy positions; support/partner with small businesses owned by minoritized group members | “Develop concept for in-market research employing … Black Sales reps in Core inner city sales territories” (Davis 1978, p. 10). “Tie-in with any company who help black—‘we help them, they help us.’ Target group age 16+” (Davis 1978, p. 8). | - 2022: R. J. Reynolds enlisted Black lobbyists and a Black former member of Congress to oppose menthol bans and overestimate the impact of menthol bans on retailers (Baumgaertner et al. 2022).; - 2020: Altria subsidiary John Middleton Co. (Black & Mild cigars) announced Closing the Gap, a business initiative designed to donate to “nonprofits that support Black-owned businesses in our community, strengthen relationships and continue spending toward Black-owned vendors and suppliers, [and] utilize our marketing efforts to amplify Black-owned businesses” (Trinkets & Trash 2020b).; - 2020: Swisher Sweets announced an inclusion, diversity, and transformation strategy to “partner with multicultural groups …, create opportunities for Black-owned businesses, develop a talent pipeline with Historically Black Colleges and Universities, [and] create sustainable corporate and field career opportunities for minorities within Swisher International” (Trinkets & Trash 2020a).

### Present: Building Momentum for Health and Racial Equity

In 2020, racial and ethnic disparities in the burden of COVID-19 and the killing of George Floyd and other unarmed Black or African American people by police elevated awareness of the impact of racial inequity in the media and public dialogue (Heley et al. 2023). In January 2021, a presidential executive order on advancing racial equity and support for underserved communities through the federal government was released (The White House 2021). In April 2021, the director of CDC declared racism to be a serious public health threat and announced efforts to advance science, invest in communities, foster diversity and inclusion, catalyze public and scientific discourse around racism and health, and be accountable for progress (CDC 2021b). The present report identifies tobacco-related health disparities as a social injustice and acknowledges poverty and discrimination as key drivers of disparities.

Even as these important developments unfolded, the tobacco industry co-opted racial justice and civil rights as themes in its marketing and community engagement efforts. Heley and colleagues (2023) examined how manufacturers of cigars, cigarillos, and hookah integrated the #BlackLivesMatter hashtag into social media advertising and cigar merchandise. No such marketing was found for tobacco products, such as smokeless tobacco, that are more commonly used by White people (Heley et al. 2023). Appropriating the #BlackLivesMatter hashtag in marketing demonstrates how the tobacco industry undermines tobacco control efforts through continued engagement with communities harmed by tobacco-related health disparities. Efforts by Reynolds American Inc., which markets Newport and Camel cigarettes, to oppose bans on menthol cigarettes have included (a) hiring a team of Black influencers and lobbyists who have claimed that banning menthol cigarettes would increase policing in Black communities (Baumgaertner et al. 2022) and (b) offering a pastor in Detroit hundreds of thousands of dollars to campaign against a menthol cigarette ban, which he rejected (The Bureau of Investigative Journalism 2022). Importantly, however, other Black advocacy groups, including the National Association for the Advancement of Colored People (NAACP), contend that “the industry and its allies stoked fears that banning menthol would lead to more overpolicing in Black communities,” but “[b]anning menthol will save Black lives” (Johnson 2023).

Although momentum to combat systemic inequity has accelerated, progress in tobacco prevention and control has stalled in many places across the United States, exacerbating geographic disparities in access to effective interventions. As of 2022,

- Twenty-two states, mostly concentrated in the South and Midwest, as well as Guam and the Northern Mariana Islands “do not yet have in place comprehensive smokefree indoor air laws covering all bars, restaurants, and worksites,” (CDC 2022e) and no new comprehensive smokefree laws have been enacted at the state level since 2012 (Holmes et al. 2016).
- Thirteen states tax cigarettes at a rate of less than $1.00 per pack, and four states tax cigarettes at less than $0.50 per pack (CDC 2022b). Only 16 states tax little cigars at the same rate as cigarettes (CDC 2022b). Meanwhile, federal tobacco taxes have not increased in more than a decade (Holmes et al. 2016; CDC 2022b).
- Thirty-one states lack comprehensive Medicaid coverage for tobacco cessation treatments, defined as coverage of individual counseling, group counseling, and all seven FDA-approved cessation medications (CDC 2022c).
- Many local efforts are hampered by preemption at the state level. For example, as of June 30, 2022, 12 states have laws or court decisions in effect that explicitly preempt local ordinances from restricting smoking in government worksites, private worksites, restaurants, or bars (CDC 2022d).

Meanwhile, the tobacco industry continues its marketing, research and development, litigation against public health policies, lobbying, and public relations efforts (World Health Organization 2008). The tobacco product landscape has diversified to include (a) combustible tobacco products, which are responsible for the overwhelming burden of tobacco-related death and disease in the United States (USDHHS 2014); (b) a rapidly expanding array of noncombustible tobacco products, including smokeless tobacco products, e-cigarettes, heated tobacco products, and oral nicotine products marketed for nontherapeutic purposes; and (c) an expanding portfolio of flavors that mask the harsh taste of tobacco, make tobacco products appealing and harder to quit, and contribute to disparities in initiation and successful cessation. Through such public relations efforts as the “Foundation for a Smoke-Free World,” which was established by Philip Morris International in 2017,^1^ the industry has promoted itself as a leader in the fight to eliminate smoking (but not the use of other tobacco products)—even as it heavily relies on revenues from the sale of cigarettes (including menthol cigarettes) and other combustible tobacco products. Specifically,

- Altria, which makes Marlboro cigarettes and Black & Mild cigars and had a significant minority stake in e-cigarette brand JUUL until March 2023, revealed in its 2021 earnings report that it made 87% of its total revenues from combustible tobacco products (Altria Group 2021).
- British American Tobacco (2022), which owns the Newport and Camel menthol cigarette brands through its Reynolds American Inc. and R.J. Reynolds Tobacco subsidiaries, reported that 86% of its 2021 revenue was from combustible tobacco products.

Efforts to rapidly eliminate the use of combustible tobacco products by addressing their availability, appeal, and addictiveness will reduce the burden of tobacco-related death and disease (USDHHS 2014).

Although progress in commercial tobacco control has stalled in many places, some states and localities have moved forward with efforts to address tobacco-related health disparities. For example,

- As of December 2023, two states (California and Massachusetts) and nearly 200 communities have prohibited the sale of flavored tobacco products, including menthol cigarettes, protecting about one-sixth of the population (Campaign for Tobacco-Free Kids 2023; Truth Initiative 2023).
- In October 2021, the Navajo Nation Council passed the Niłch’ éí Bee Ííńá (Air is Life) Act of 2021, a 100% commercial tobacco smokefree policy for the Nation with no exceptions, including casinos. The act is the first comprehensive ban on the use of all commercial tobacco products on American Indian tribal lands (Nez Henderson and Leischow 2022).
- Between 2008 and 2022, the number of states with comprehensive coverage for tobacco cessation treatments for all traditional Medicaid enrollees increased from 6 to 19 (DiGiulio et al. 2020; CDC 2022c).

Success in advancing tobacco-related health equity relies on building momentum to secure optimal outcomes for all people. Achieving tobacco-related health equity also hinges on future implementation efforts that (a) address social and structural determinants of health disparities; (b) leverage strong multisector partnerships and strategic and sustainable investments; and (c) engage meaningfully with communities that are most affected by health disparities in all phases and stages of strategic implementation.

#### Comprehensive Tobacco Treatment Remains Inaccessible to Many People with Lower Incomes Who Use Tobacco

As described in Chapter 4, provisions in the Patient Protection and Affordable Care Act (ACA) require comprehensive coverage of tobacco cessation treatments for pregnant adults enrolled in Medicaid. In addition, comprehensive coverage is required for (a) all enrollees in expanded Medicaid in states that choose to expand Medicaid coverage pursuant to the ACA and (b) enrollees in most private health plans, including all plans sold in federal or state exchanges (CDC 2021a). However, analyses conducted in 2018 (McMenamin et al. 2018) and 2020 (DiGiulio et al. 2020; McMenamin et al. 2020) revealed that efforts to expand Medicaid coverage of cessation treatments have been mixed. For example, although coverage of all nine evidence-based tobacco cessation treatments (individual and group counseling and seven FDA-approved medications) for traditional Medicaid enrollees has improved over time, the number of state Medicaid programs with such comprehensive coverage remains low. Further, there are common barriers to accessing services—such as copays, prior authorizations, and limits on services based on the number of quit attempts (DiGiulio et al. 2020; CDC 2022c). Adequately promoted, comprehensive, barrier-free, and evidence-based cessation insurance coverage increases the availability and utilization of cessation treatment services (USDHHS 2020). The full implementation of the ACA and wide availability of comprehensive, barrier-free coverage of tobacco cessation treatments for all Medicaid enrollees has the potential to contribute to substantial reductions in tobacco use among Medicaid enrollees. Additional studies are needed to determine the extent to which such implementation may close the tobacco-related disparities gaps between people who are enrolled in Medicaid and those who are not.

### Future: Ending the Tobacco Use Epidemic for All

#### Progress and Challenges

In April 2022, FDA issued proposed product standards to prohibit menthol as a characterizing flavor in cigarettes and prohibit all characterizing flavors (except tobacco) in cigars (Federal Register 2022a,b). In addition to explaining that these measures are appropriate for the protection of public health, FDA noted that the proposed rules are also expected to reduce tobacco-related health disparities and advance health equity (Federal Register 2022a,b; Zeller 2022). FDA projects that, if finalized, the proposed product standards would have major impacts on public health. A federal regulation on menthol cigarettes and flavors in cigars is expected to reduce tobacco use initiation among youth and young adults and reduce disparities in tobacco use and quitting among people who predominantly use flavored commercial tobacco products (FDA 2022b).

In addition, FDA signaled, by including it in the spring 2022 Unified Agenda of Regulatory and Deregulatory Actions, its intention to reduce addictiveness by advancing a product standard to reduce nicotine in cigarettes and certain other combustible tobacco products (FDA 2022a). Such an action has been projected to prevent more than 33 million people from starting to smoke, result in an adult smoking prevalence of 1.4%, and prevent more than 8 million people from dying from tobacco-related illnesses by the year 2100 (Apelberg et al. 2018). Additional research can provide information about the impact of reduced nicotine on reducing tobacco use, promoting quitting, and eliminating health consequences among minoritized racial and ethnic groups, people with lower socioeconomic status, and other groups who experience disparities.

Historical and present-day tactics of the tobacco industry (Table 8.1) suggest that public health efforts to reduce tobacco use and eliminate disparities—including menthol and cigar flavor restrictions—will be met with tobacco industry opposition at local, state, and federal levels through litigation, ballot initiatives, and direct and indirect (grassroots) lobbying. For example, as of April 2024,

- Tobacco companies effectively delayed implementation of California’s statewide restriction on the sale of flavored tobacco products, which was enacted in 2020. Specifically, Philip Morris USA, R.J. Reynolds, ITG Brands, Swedish Match, and the National Association of Tobacco Outlets funded a referendum to overturn the law. On November 9, 2022—the day after California voters overwhelmingly approved the law—R.J. Reynolds filed a lawsuit to challenge the law and seek an injunction against its implementation, which the U.S. Supreme Court rejected (Public Health Law Center at Mitchell Hamline School of Law 2020). In January 2024, the U.S. Supreme Court again rejected an appeal from R.J. Reynolds contending that California’s law was preempted by federal law (Raymond 2024).
- Tobacco product manufacturers, tobacco retailers, tobacco retailer associations, and/or cigar trade associations have pending lawsuits against the state of California and cities in Oregon to challenge restrictions on flavored tobacco products.
- Litigation initiated by R.J. Reynolds and Philip Morris USA to block the U.S. government from implementing pictorial warnings on cigarette packages is ongoing.

The tobacco industry is also expected to continue to seek ways to circumvent restrictions through product design and marketing tactics. As documented in Chapter 3, after California’s menthol cigarette and other flavored tobacco product restriction became effective, R.J. Reynolds began marketing cigarettes containing the odorless and tasteless synthetic cooling agent WS-3 using the descriptor “non-menthol.” In addition, in 2021, manufacturers of some e-cigarettes and nicotine pouches began marketing products in the United States with synthetic nicotine not derived from tobacco. These products, which are offered in flavors known to appeal to youth and are marketed for discreet use (Marynak et al. 2021), fell outside the federal statutory definition of tobacco products. On March 15, 2022, Congress granted FDA authority to regulate tobacco products containing nicotine from any source (FDA 2022c); however, gaps remain in some local and state statutes (Berman 2021; Public Health Law Center 2022). As documented in the 2014 and 2016 Surgeon General’s reports (USDHHS 2014, 2016), sufficient scientific evidence about nicotine exists to (a) warn young people and pregnant adults against using nicotine from any source and (b) justify incorporating nontobacco nicotine products into existing tobacco product regulation, surveillance, and health communication and marketing efforts.

Nevertheless, future tactics from the tobacco industry to circumvent regulations, such as reductions in nicotine in cigarettes to reduce addictiveness, may include the use of nicotine analogs (i.e., compounds with similar pharmacologic properties to nicotine but with different chemical structures). Previously internal industry documents released during litigation reveal that tobacco companies have extensively investigated nicotine analogs, including for the purposes of circumventing future regulations (Vagg and Chapman 2005). Beginning in October 2023, at least one brand of e-cigarette products entered the U.S. market asserting that it contains a “synthetically derived molecule that is structurally similar to, but chemically different from, other vaping alkaloids [and] … produces the same sensation as nicotine” (Jordt et al. 2023, citing SPREE BAR 2023). With claims that the products are exempt from regulation, the products are offered in appealing flavors, such as Rainbow Fruit, and packages feature images of young models with stylish sunglasses and blue lipstick. To foreclose these tactics, local, state, territorial, tribal, and federal policymakers could broaden definitions in their tobacco control laws to apply to products that contain nicotine or nicotine analogs from any source and authorize their regulation. Policymakers also could broaden definitions in flavored sales prohibitions to include products with somatosensory properties such as cooling.

Other countries’ efforts to address flavored tobacco products also provide important insights into potential future strategies by the tobacco industry to circumvent restrictions. For example, in May 2020, the European Union banned cigarettes with characterizing flavors, including menthol-characterizing flavor (European Network for Smoking and Tobacco Prevention 2020). Before and immediately after the effective date of the European Union ban, Japan Tobacco International introduced multiple brands of Winston cigarettes that (a) were found in laboratory analyses to contain substantially more menthol than regular (i.e., tobacco flavored) cigarettes and (b) used blue or green packaging to suggest menthol’s presence, but without using the descriptor menthol (Ciurcanu and Cerantola 2021). These tactics underscore the importance of monitoring tobacco products marketed as tobacco flavored and the levels of menthol, synthetic coolants, and other additives that invoke multisensory flavor experiences.

Given the tobacco industry’s past and present efforts to delay, block, or avoid the implementation of federal regulations (World Health Organization 2008; Marynak et al. 2021), localities, states, tribes, and territories should not wait for the implementation of federal strategies to address tobacco-related health disparities. Importantly, the Family Smoking Prevention and Tobacco Control Act of 2009 preserves state, local, tribal, and territorial governments’ authority to enact any policies “in addition to, or more stringent than, requirements established under this chapter [of the Tobacco Control Act], including a law, rule, regulation, or other measure relating to or prohibiting the sale, distribution, possession, exposure to, access to, advertising and promotion of, or use of tobacco products by individuals of any age” (FDA 2018). This preservation of state and local authority ensures the continuation of community-driven health equity initiatives.

#### Common Threats Between Commercial Tobacco and Cannabis

Cannabis use represents an important public health concern, especially given the high prevalence of tobacco and cannabis co-use in youth and young adults; social, economic, and health disparities associated with chronic cannabis use; and disparities in exposure to secondhand cannabis smoke by age and race and ethnicity (University of California–Davis Health System 2016; Terry-McElrath et al. 2017; Substance Abuse and Mental Health Services Administration 2021). Although efforts to decriminalize cannabis possession and reschedule cannabis under federal law are important to redress racial and ethnic disparities in the criminal justice system (The White House 2022), the issue of decriminalization is distinct from health-related concerns about exposure to cannabis smoke. The increased legalization of recreational cannabis at state and local levels represents a threat to smokefree norms and protections and has implications for health disparities (Jacobus and Tapert 2014; D’Souza et al. 2016; Substance Abuse and Mental Health Services Administration 2020, 2021). As of July 2022, two states (Colorado and Nevada) with statewide smokefree laws contain an exemption for cannabis smoking in 100% smokefree restaurants and one state (Michigan) contains an exemption for cannabis smoking in 100% smokefree restaurants and bars (American Nonsmokers’ Rights Foundation 2022). Although the short- and long-term health effects of exposure to cannabis smoke are unknown (National Academies of Sciences, Engineering, and Medicine 2017), a World Health Organization (2016) review concluded that evidence suggests that cannabis smoke is carcinogenic, and California added cannabis smoke to its list of carcinogens, as required under California Proposition 65 (California Office of Environmental Health Hazard Assessment n.d.). Studies suggest that many of the same constituents of tobacco smoke are present in cannabis smoke; some constituents (e.g., ammonia and hydrogen cyanide) are higher in concentration in cannabis smoke than in tobacco smoke (Moir et al. 2008; Tomar et al. 2009). Furthermore, the commercial tobacco industry is investing heavily in commercial cannabis and seeking to shape regulations for and policies about cannabis (Dewhirst 2021), which may undermine efforts to address health disparities and specifically jeopardize efforts to promote equitable smokefree protections.

#### Misinformation and Tobacco Industry Interference in Science

Although not a recent phenomenon, health misinformation spread at unprecedented speed and scale during the COVID-19 pandemic and with significant negative consequences (USDHHS 2021) This has important implications for the present and future of tobacco prevention and control. Confronting Health Misinformation: The U.S. Surgeon General’s Advisory on Building a Healthy Information Environment documents how misinformation led to public confusion and mistrust about COVID-19 health information (USDHHS 2021). The advisory notes that experiences of racism in the healthcare system and increasing political polarization may also facilitate the spread of misinformation in some communities. Mistrust in science and medicine and of scientists, healthcare professionals, and public health officials could hamper efforts to eliminate tobacco-related health disparities and educate the public about both the health consequences of tobacco use and the health benefits of tobacco cessation. Furthermore, the tobacco industry could use mistrust opportunistically to further undermine evidence-based tobacco control strategies (Albarracin et al. 2018; Tan and Bigman 2020), including by attempting to frame restrictions on flavored tobacco products as contrary to social justice, as described previously.

Briggs and Vallone (2022, p. 388) noted that the tobacco industry is “once again infiltrating scientific spaces and presenting a direct threat to the vital work of unbiased tobacco control scientists.” Tobacco industry sponsorship of published scientific research is strongly associated with research results that are favorable to the tobacco industry (Shaw et al. 2016; Hendlin et al. 2019; Pisinger et al. 2019; Tan et al. 2019). Additional tactics by the tobacco industry to distort knowledge ecosystems and alter public perceptions include publishing sponsored research; sponsoring special journal supplements; rebranding efforts that project concern for consumer health and wellness despite continued marketing of combustible tobacco products; participating in academic conferences; and “appropriating the language of harm reduction” while muddying debate within the broader research and public health community (Briggs and Vallone 2022, p. 389). Industry funding of and participation in research may also be used to cast doubt about promising strategies to reduce tobacco-related health disparities, such as restrictions on flavored tobacco products (World Health Organization 2008). Because the activities of the tobacco industry are “incompatible” with public health objectives (World Health Organization 2008), it is critical to anticipate, recognize, and reject conflicts of interest in scientific, policy, and regulatory arenas.

Finally, state laws passed to restrict local authority in the wake of COVID-19 could also present challenges for tobacco control efforts, particularly in states in the South and Midwest that are already characterized by a higher prevalence of tobacco use, poorer health outcomes, and lower socioeconomic status (Truth Initiative 2019). For example, in June 2021, West Virginia enacted a law that requires any new rules from a local board of health to be approved, disapproved, or amended by the county or city that authorized the creation of that board of health (The Network for Public Health Law 2022). Before this, more than half of West Virginia’s population gained protection from exposure to secondhand smoke because of the adoption of smokefree rules by local boards of health, which required no approval by a legislative body (West Virginia Department of Health and Human Resources 1995; Marino 2021). However, as of May 2023, no new smokefree rules have been adopted by a local board of health in West Virginia since the June 2021 law was enacted (American Nonsmokers’ Rights Foundation 2023). The placement of limits on public health authority driven by concerns about nontobacco health issues could also affect the ability to prevent and control tobacco use and exposure to second-hand tobacco smoke at the local level, such as through tobacco price increases and smokefree laws, and exacerbate geographic disparities in states with a high prevalence of tobacco use.

#### A Health Equity Lens on Population-Level and Endgame Strategies

This report reinforces the evidence that long-standing, core population-level strategies—such as implementing price increases, smokefree air policies, and hard-hitting media campaigns and providing cessation resources—are effective components of a comprehensive tobacco prevention and control strategy. Further, this report acknowledges inequitable progress in implementing these strategies, while also revealing the dearth of evaluations to assess the impact of population-level strategies on reducing tobacco-related health disparities. But even if core tobacco prevention and control strategies such as smokefree protections were implemented equitably and comprehensively, they would not be sufficient to end the epidemic of tobacco-related death and disease (USDHHS 2014, 2020). Social, structural, and commercial determinants of health must be addressed to produce an endgame in which zero lives are harmed by or lost to tobacco. What is clear, however, is that current gaps in the equitable implementation of effective strategies exacerbate disparities and must be closed.

To move the field forward in the context of uneven progress and evolving science, tobacco control strategies may be analogized as tools in a shed, with ample shelf space for both (a) proven population-level strategies and (b) promising strategies to advance tobacco-related equity. This toolshed of tobacco control strategies can be continually expanded to accommodate new approaches that advance tobacco-related health equity, particularly if well-designed studies free of influence from the tobacco industry demonstrate their effectiveness. For example, in addition to proven population-level strategies such as smokefree policies, evidence presented in this report supports restricting nicotine levels and flavors in tobacco products, requiring minimum prices (such as through an established price floor and prohibiting price discounts), and reducing the density of tobacco retailers (see Chapter 7). Robust science that takes into consideration the social and structural determinants of health is pivotal to building the evidence for what works, in what circumstances, and for whom—and understanding what does not work—to maximize benefits for public health and minimize the opportunity costs of efforts.

#### Recent Advancements in Equity-Informed Approaches

The experiences of tobacco control practitioners who have achieved recent successes in advancing evidence-based and promising interventions to advance tobacco-related health equity show that progress is achieved through a commitment to core principles under a theory of social justice, including equal respect, knowledge and understanding, self-determination, and power sharing. For example,

- The African American Tobacco Control Leadership Council’s successful efforts to advocate for a comprehensive ban on the sale of flavored tobacco products in San Francisco (Mills et al. 2021) demonstrate the importance of (a) building relationships of trust with communities that are affected by inequities before asking for their support (Malone 2021) and (b) listening to and clearly and consistently addressing community concerns (Mills et al. 2021).
- In addition, the 13-year journey to enact the Navajo Nation’s Air is Life Act offers important insights that can inform future efforts (Nez Henderson and Leischow 2022). A series of failures to pass the legislation led those involved in research and advocacy to refocus efforts to better understand how Navajo healers, tribal elders, and other community leaders view traditional or ceremonial tobacco versus commercial tobacco, and how they share related knowledge and information and community concerns about policies. Findings informed public education efforts, and a series of meetings between researchers, advocates, and community leaders used relevant data on the economic impacts and health benefits of smokefree policies to allay concerns.
- Successes in San Francisco and the Navajo Nation have helped to build momentum for a statewide ban on flavored tobacco products in California and for a smokefree policy in the Eastern Band of Cherokee Indians in North Carolina (Nez Henderson and Leischow 2022).

These collaborative efforts exemplify commitment to sharing power, which involves transforming community concerns into actionable initiatives and active, transparent, and frequent communication that eliminates silos between public health, academic institutions, and other community organizations to advance tobacco-related health equity (Wallerstein et al. 2019).

At a basic level, commitment to fostering equal respect and knowledge and understanding hinges on the measurement of self-identified characteristics and self-reported drivers of inequities (e.g., social determinants or conditions), including through nationally representative surveys of youth and adults (Powers and Faden 2019). As Malone (2021, p. e76) notes, “for some disadvantaged populations, it has been a real fight to simply become recognized and visible enough to have data systematically collected for research.” Researchers must protect recent advancements in measurement; further advance measurement of structural and social determinants of health across the lifespan (e.g., discrimination, built environment); advocate for disaggregation in measurement and oversampling of disparate populations; and assess markers of disparity, such as constructs related to sexual orientation and gender identity. Such data will inform interventions to address social and structural determinants among intersectional groups.

Achievement of optimal individual health requires that health systems and other institutions facilitate knowledge and understanding that drives (a) decisions to quit or never use tobacco products, (b) access to and utilization of cessation resources, and (c) measurement thereof. Taking action to curtail exposure to marketing of and the use of commercial tobacco products—whether through clinical, community, or policy interventions—demonstrates respect and regard for communities with a long history of disparities. Curtailing tobacco use through such interventions provides communities with opportunities to determine their own fate and to inform the delivery of health-promoting interventions that are free from the influences of the tobacco industry and the social and structural drivers of health disparities.

Importantly, policies that preempt local authority to protect the public’s health are incompatible with self-determination, which focuses on cultivating the capacity for self-direction (Powers and Faden 2019). Preemption of local authority represents a persistent threat to health equity goals across multiple dimensions, including but not limited to protecting infants, children, and adults from the harms of commercial tobacco use and/or exposure, as documented in previous Surgeon General’s reports (USDHHS 2014, 2016).

#### A “Both/And” Approach to Tobacco-Specific and Social and Structural Interventions

Interventions that are solely focused on tobacco product use and exposure, rather than social and structural drivers of multidimensional disparities, are unlikely to sustainably promote health equity across its multiple dimensions (including but not limited to other risk factors for chronic disease as poor diet, physical inactivity, social isolation, and excessive alcohol use). Social and structural interventions—or efforts to “change the social, physical, economic, or political environments that shape or constrain health” including by addressing social determinants of health such as limited educational and employment opportunities, safe and quality housing, and discrimination—are worthy of attention and engagement by groups that have historically focused on more narrowly defined behaviors and outcomes (National Institutes of Health 2022). For example, data presented in Chapter 2 and in Figures 8.1 and 8.2 demonstrate that disparities in smoking by race and ethnicity or by sexual orientation narrow or disappear altogether among those with incomes greater than twice the poverty level. A both/and approach—combining tobacco-specific interventions with social and structural determinant interventions—is warranted to maximize the impact of efforts on tobacco-related health equity, particularly given the explicit tactics of the tobacco industry to target communities and undermine public health efforts.

Recognizing that cross-cutting efforts are needed that shift from siloed approaches “tackling inequities one disease, organ system, or life stage at a time,” the National Institutes of Health announced the Community Partnerships to Advance Science for Society (ComPASS) strategy to address structural factors that impact multiple dimensions of health (National Institutes of Health 2022). It will be critical to measure the potential impact of these efforts on tobacco-related health equity, and for organizations typically involved in more narrowly defined efforts (i.e., tobacco control) to participate in and learn from these efforts.

#### Considerations for Advancing Equity in Endgame Approaches

The 2014 and 2020 Surgeon General’s reports on tobacco (USDHHS 2014, 2020) offered recommendations to advance the tobacco endgame to eliminate the burden of death and disease caused by commercial tobacco use. The 2014 report concluded that “the burden of death and disease from tobacco use in the United States is overwhelmingly caused by cigarettes and other combustible tobacco products; rapid elimination of their use will dramatically reduce this burden” (USDHHS 2014, p. 7). Both reports acknowledged that without endgame solutions, population-based tobacco prevention and control strategies are necessary but insufficient to end the tobacco epidemic. Two strategies to advance the tobacco endgame were prominently discussed in the 2014 and 2020 reports:

- Implementing a tobacco product standard to lower the level of nicotine in cigarettes to minimally addictive or nonaddictive levels; and
- Restricting the sale of tobacco products, such as prohibitions on entire categories of tobacco products.

Figure 8.1 Prevalence of current use of cigarettes among adults, 18 years of age and older, by race and ethnicity and socioeconomic status;^a^ a Socioeconomic status was assessed by calculating the ratio of family income to the corresponding poverty threshold. National Health Interview Survey (NHIS) 2019–2021 combined data, United States

Among people experiencing poverty, defined as living below the poverty level, the prevalence of current use of cigarettes among adults was highest among Other, multiple race people, followed closely by White people and then by American Indian and Alaska Native people and Black people. Disparities in smoking by race and ethnicity narrow or disappear altogether among those with incomes greater than twice the poverty level. Across all levels of poverty, such prevalence was consistently lowest among Hispanic and Asian adults.

Source: NHIS, National Center for Health Statistics, public use data, 2019–2021.

Figure 8.2 Prevalence of current use of cigarettes among adults, 18 years of age and older, by sexual orientation and socioeconomic status;^a^ a Socioeconomic status was assessed by calculating the ratio of family income to the corresponding poverty threshold. National Health Interview Survey (NHIS) 2019–2021 combined data, United States

^b^The minoritized sexual orientation group includes adults who identified as gay, lesbian, or bisexual or who reported “something else.”

Among people living below the poverty level and at 1-<2 times the poverty level, current use of cigarettes among adults was higher among people in minoritized sexual orientation groups than it was among people who identified as heterosexual. Disparities in smoking by sexual orientation disappeared among those with incomes greater than twice the poverty level. The prevalence of current cigarette use in each group defined by sexual orientation decreased as the level of poverty increased, and the difference in such use between these two groups decreased as the level of poverty increased.

Source: NHIS, National Center for Health Statistics, public use data, 2019–2021.

Progress has occurred in these domains in recent years, particularly in terms of local policies that prohibit the sale of menthol and other flavored products or of tobacco products altogether, but the end is not yet in sight. As noted earlier, FDA has advanced proposed rules to prohibit menthol as a characterizing flavor in cigarettes and to prohibit characterizing flavors in cigars (Federal Register 2022a,b) and also announced its intention to advance a product standard to reduce nicotine in cigarettes and certain other combustible tobacco products to minimally addictive or nonaddictive levels (Federal Register 2018).

There remains, however, a lack of consensus about whether endgame strategies should seek to eliminate combustible tobacco product use or to eliminate all tobacco product use. Because the tobacco industry has an obvious financial stake in preferred endgame objectives, it is important to consider conflicts of interest in the industry’s efforts to influence endgame planning (Briggs and Vallone 2022).

Importantly, dialogue around the endgame has evolved to focus not only on tobacco use by individuals but also on the tobacco industry’s influence on society. For example, the UNDO project from the California Department of Public Health frames endgame initiatives as an effort to “undo the tobacco industry’s influence” on individuals, communities, and society (UNDO n.d.). Similarly, Malone and colleagues (2014, p. 10) frame endgame strategies as “[I]nitiatives designed to change/eliminate permanently the structural, political and social dynamics that sustain the tobacco epidemic, in order to achieve within a specific time an endpoint for the tobacco epidemic.” Structural dynamics include the inequitable distribution of burdens that perpetuate use, including retailer density; political dynamics include industry lobbying, community engagement (including allyship) and front groups; and social dynamics include the public’s acceptance of the sale of addictive, deadly products. “For any endgame plan,” Smith and Malone (2020, p. 705) later wrote, “the narrative about cigarette sales must shift to end the perception that cigarettes are an ordinary consumer product. Rather, selling cigarettes should be characterised as selling an inherently defective/unsafe product that falls into the same category as contaminated food, asbestos and lead paint.” Similarly, Malone and Proctor (2022, p. 376) advocate for framing the end of tobacco sales as a strategy to “enhance human health and freedom” rather than prohibition—a polarizing term implying a loss of freedom that they believe has served as an obstacle to meaningful dialogue on endgame solutions.

To advance human well-being, tobacco endgame strategies must also ensure that groups disproportionately burdened by tobacco-related morbidity and mortality (within and across population groups), which are often the same groups facing other forms of structural and social disadvantage, are given primary consideration, are not an afterthought, and are meaningfully seated at the proverbial and strategic discussion table. Unless equity is a central focus of efforts, the possibility exists for endgame approaches to

- Exacerbate existing disparities, for example, if they are concentrated in high-resource communities or supplant efforts to address social and structural determinants of health; or
- Be used by the tobacco industry to justify targeted marketing of (a) e-cigarettes and other products that are promoted as “reduced-harm” and (b) commercial cannabis to population groups that are already burdened by health-related disparities and that would otherwise completely quit using tobacco products.

Given these considerations, the overriding objective of endgame efforts is to advance health equity by creating and promoting fair and just opportunities and social, structural, and political conditions for all people to live a healthy life that is free from commercial tobacco-related disease, disability, and death. Table 8.2 outlines examples of potential health equity safeguards in endgame approaches to simultaneously address the appeal (including flavors), addictiveness (including nicotine levels), and availability of commercial tobacco products (including sales, marketing, and retailer density). These efforts to reduce appeal, addictiveness, and accessibility would be expected to result in true harm reduction at the population level. Tobacco-specific endgame interventions should complement, not replace, practices to remove the underlying social, structural, and political barriers to health equity (Table 8.3).

Endgame approaches should incorporate health equity safeguards. For example, an approach to comprehensively address appeal and addictiveness is important to optimally promote health equity. Specifically, given the disproportionate use of menthol cigarettes and cigars by some groups, if nicotine in cigarettes is lowered to minimally or nonaddictive levels without removing menthol, or if nicotine limits in cigarettes are not applied to other combustible tobacco products, such as cigars, then existing tobacco-related health disparities have the potential to widen, even if there is a benefit to the overall population.

Table 8.2 Health equity safeguards in endgame approaches

Potential strategy | Potential health equity safeguards
Reduce nicotine in cigarettes and other tobacco products to minimally addictive or nonaddictive levels | - Ensure parity of nicotine levels across tobacco products, including little cigars and cigarillos; - Ensure removal of menthol, mint, and other cooling chemical additives at any level across all tobacco products, including products advertised as low nicotine; - Prohibit substitution of nicotine with nicotine analogs or other additives, constituents, or components that increase the addictive nature of tobacco; authorize regulation of nicotine analogs; - Develop immediate strategic solutions to address geographic, technologic, and systemic barriers to population access to evidence-based cessation support, such as advice to quit, quitlines, reach of mass media campaigns, and no- to low-cost pharmacotherapy and behavioral cessation counseling; - Monitor and counter potential unintended consequences of tobacco policy interventions, such as switching from tobacco to cannabis, inequitable enforcement or increased profiling of communities, and illicit sales; - Equitably enforce existing and future regulations against retailers and manufacturers that continue to sell tobacco products and/or components illegally
Restrict the manufacture and/or sale of flavored tobacco products, including menthol cigarettes and flavored cigars | - Ensure removal of menthol at any level across all tobacco products, including very low nicotine cigarettes and cigars; - Eliminate chemicals, additives, constituents, and components, including sweeteners and coolants, that impart taste, smell, or sensations that reduce harshness or increase the appeal of tobacco products; - Reduce the nicotine in cigarettes and other tobacco products to nonaddictive levels; - Develop plans to enforce flavor restrictions and to penalize manufacturers, distributors, and retailers for noncompliance; - (As above) Develop immediate strategic solutions to address geographic, technologic, and systemic barriers to population access to evidence-based cessation support, such as advice to quit, quitlines, reach of mass media campaigns, and no- to low-cost pharmacotherapy and behavioral cessation counseling
Restrict consumer marketing of tobacco products | - Prioritize the enforcement of marketing restrictions on retailers (e.g., in-store and exterior ads for tobacco products at retail stores) and restrictions on marketing by tobacco company sales representatives to retailers (e.g., urging retail store owners to sign up for tobacco company “participating retailer programs,” or to increase amount of high-visibility, behind-the-counter shelf space dedicated to tobacco products) in communities with low resources and/or high densities of tobacco retailers; - Create a new public health workforce of faith leaders, community leaders, and youth and young adults who are advocates for and engage in commercial tobacco countermarketing, including countermarketing related to menthol; - Work with urban and rural development partners to transform low-resource communities into healthy communities that support the marketing, sales, and promotion of healthy products and that reject harmful products
Restrict the manufacture and/or sale of entire categories of tobacco products, such as combustible tobacco products | - Build trusting relationships across communities, conduct research to understand and address community concerns, and use messages emerging from communities to inform endgame efforts; - (As above) Create a new public health workforce of faith leaders, community leaders, and youth and young adults who are advocates for and engage in commercial tobacco countermarketing, including countermarketing related to menthol; - Work with and invest in minority-owned retailers and retailers in low-resource communities to support the marketing of healthy products and reject harmful products; - Prioritize efforts in racially, ethnically, and socioeconomically diverse communities that are disproportionately affected by tobacco marketing; - Reduce product addictiveness and appeal by eliminating flavors and lowering nicotine levels to increase the acceptability of sales bans and to reduce incentives for consumers to cross community, state, or tribal lines to purchase tobacco products; - Work with leaders of Indigenous population groups to identify replacement products for commercial tobacco products that are sold on tribal reservations and in casinos, while respecting tribal sovereignty; - Identify incentives for workplaces, including casinos, that employ wage workers to create and support smokefree air environments; - (As above) Develop immediate strategic solutions to address geographic, technologic, and systemic barriers to population access to evidence-based cessation support, such as advice to quit, quitlines, reach of mass media campaigns, and no- to low-cost pharmacotherapy and behavioral cessation counseling
Prevent sales of tobacco products to future generations | - Eliminate penalties for purchase, use, or possession of tobacco products while allowing youth to participate in appropriately supervised evaluations of retailer customer-age compliance; - Prevent substitution of cannabis, synthetic nicotine, and nicotine analogs for tobacco products.; - Prohibit internet sales of all tobacco products; - Enforce restrictions on internet sales of commercial tobacco products; - Support cessation interventions across the lifespan, including among older adults

Tobacco-related health disparities may also intensify if endgame policies only advance in high-resource communities. For example, although public support exists for restrictions on the sale of all tobacco products, with 57.3% of 6,455 adults surveyed supporting such a policy (Al-Shawaf et al. 2023), only two communities have done so: Beverly Hills and Manhattan Beach, California. The populations of these communities are more than 70% non-Hispanic White (compared with 57.8% nationwide), and the median household income exceeds $100,000 (compared with $67,521 nationwide) (U.S. Census Bureau n.d.). The solution is not to stifle endgame policy efforts; many of the most effective tobacco prevention and control interventions, such as smokefree laws, originated at the local level, including in high-resource communities, before becoming normalized and widespread (USDHHS 2014). Nevertheless, decades after the smokefree movement began, persistent inequities in protections from exposure to secondhand smoke suggest that endgame strategies will not end the tobacco epidemic unless racially, ethnically, and socioeconomically diverse communities that are disproportionately subjected to tobacco marketing and exposure are viewed as equally deserving of such efforts and are allotted equitable resources, conditions, and opportunities to lead and implement such efforts. Tobacco control practitioners can work with communities to advance approaches that emanate from and resonate with residents. Simultaneously, comprehensive federal restrictions on the appeal and addictiveness of tobacco products, including flavors and levels of nicotine, could complement a gradual phaseout of cigarette sales and reduce incentives to cross state, local, or tribal borders to purchase tobacco products (Smith and Malone 2020).

Table 8.3 Potential social, structural, and political strategies to remove barriers to tobacco-related health equity

Domain | Example strategy
Social | - Work with communities to develop and provide resources for solutions that support all dimensions of well-being and address social determinants—such as poverty, racism, and inequity—in education, healthcare, housing, and other domains; - Invest in resources to denormalize commercial tobacco products and expose tactics of the tobacco industry; - To the extent legally permissible, restrict commercial tobacco advertising, sponsorship, and product placement, particularly in communities that are disproportionately harmed by commercial tobacco products; - Invest in resources in communities to (re)construct a culture of health and deconstruct a culture of tobacco use promoted through targeted marketing
Structural | - Invest in resources to advance equity in access to high-quality and affordable education, transportation, housing, jobs, and mental and physical healthcare; - Divest from the commercial tobacco industry; - Commit funding to support community-based and/or academic institutions that monitor (a) the implementation of commercial tobacco control policies and (b) emerging tobacco industry tactics to expand product markets to disparate communities; - Reduce the disproportionate concentration of tobacco retailers in neighborhoods that are economically disadvantaged; have greater concentrations of residents from minoritized racial and ethnic groups; and have greater concentrations of people who identify as LGBTQI+; - Launch new partnerships to collaborate on ways that the U.S. Department of Health and Human Services, including the U.S. Food and Drug Administration, can work together with law enforcement agencies to address systemic racism and ensure equitable enforcement of commercial tobacco control policy protections, holding industry, businesses, and law enforcement agencies accountable rather than individuals and communities; - Invest in resources to convene and support urban and rural development partners to redesign low-resource communities into healthy communities that support the marketing, sales, and promotion of healthy products and that reject harmful products
Political | - Identify and eliminate potential conflicts of interest in policy development and implementation processes and hold actors accountable for avoiding conflicts of interest; - Counter protobacco influences, including through litigation and industry, legislative, and regulatory mechanisms; - Eliminate preemption and preserve authority to enact more protective measures at lower levels of government

Efforts to curtail the social, structural, and political dynamics that perpetuate the tobacco industry’s influence on society are essential complements to endgame policy approaches. Table 8.3 provides examples of these potential strategies, which align with Figure 1.1 in Chapter 1 of this report by seeking to (a) change the social context that manifests as systems, institutions, policies, and funding and investment; and (b) closely regulate channels used by the tobacco industry that result in tobacco-related health disparities, including marketing, supply, and corporate citizenship. Emerging funding efforts, such as the aforementioned ComPASS program from the National Institutes of Health, aim to fund community-led organizations to develop and implement health equity structural interventions and intervene on structural factors that produce and perpetuate health disparities. To ground and bolster these complementary equity-oriented solutions in tobacco endgame strategies, meaningful community participatory and collaborative approaches with decision makers and other multisectoral partners (e.g., tobacco control, public health, public policy, research, healthcare, and civil rights organizations) are needed in all phases and stages of work (Organizing Committee for Assessing Meaningful Community Engagement in Health & Health Care Programs & Policies 2022).

Finally, as previous Surgeon General’s reports on tobacco have emphasized (USDHHS 2014, 2020), endgame approaches, including structural interventions, should complement tobacco prevention and control strategies proven to reduce tobacco use at the population level, such as tobacco price increases, comprehensive smokefree policies, hard-hitting media campaigns, and barrier-free cessation support.

## The Call to Action

The 1998 Surgeon General’s report was the first to focus exclusively on tobacco-related health disparities in racial and ethnic groups (USDHHS 1998). Surgeon General David Satcher, who commissioned the 1998 Surgeon General’s report, stated that, “to eliminate disparities in health, we need leaders who care enough, know enough, will do enough, and are persistent enough” (Satcher and Higginbotham 2008, p. S10). A whole-of-society approach is needed that holds institutions, leaders, and individuals accountable for progress (Mills et al. 2022). This call to action includes strategies to address root causes of tobacco-related health disparities and their social, structural, economic, and political dimensions.

### What Governments (Including Those at the Local, State, Territorial, Tribal, and Federal Levels) Can Do

- Prioritize and invest in initiatives that directly support changing the structural and social determinants of health that drive tobacco-related health disparities. This includes investments in communities and multisectoral collaborations to address the built environment, social and community contexts, quality of and access to education and healthcare, and structural racism and discrimination.
- Incorporate social determinant interventions as part of a comprehensive tobacco prevention and control approach. This includes providing resources to support social determinant interventions that address the conditions in which people are born, grow, work, live, and age within CDC’s Best Practices for Comprehensive Tobacco Control Programs—2014 (CDC 2014) (Table 8.3).
- Prioritize geographic areas and populations that are not yet protected by evidence-based tobacco control interventions, including comprehensive smokefree protections and price increases for tobacco products. Dedicate revenue from tobacco excise taxes to advancing tobacco-related health equity. Work with communities, academic partners, and other interested partners to develop novel and strategic initiatives that support the implementation of such interventions while addressing social determinants.
- Invest in robust surveillance systems that measure self-identified characteristics among youth and adults who are at increased risk for tobacco use and targeted marketing by the tobacco industry, disaggregated sociodemographic constructs and other markers of disparity, and social determinants of health and other drivers of commercial tobacco-related disparities. Invest in oversampling of population groups that are subject to tobacco-related health disparities, for example in alignment with CDC’s Identifying and Eliminating Tobacco-Related Disparities: Key Outcome Indicators for Evaluating Comprehensive Tobacco Control Programs—2014 (CDC 2022a).
- Advance endgame approaches that fundamentally alter the appeal, addictiveness, and availability of commercial tobacco products. Ensure that endgame approaches advance health equity, are accompanied by meaningful expansion of access to and utilization of evidence-based cessation treatments, and employ safeguards against unintended consequences (Table 8.2).
- Ensure equitable policy protections for individuals, including nonselective implementation and enforcement (Box 8.1).
- Work with healthcare organizations to support innovative healthcare delivery models (e.g., telehealth, population management strategies) that increase access to cessation services. This includes supporting reimbursement of such services and robust evaluation of effectiveness, particularly in populations impacted by tobacco-related disparities. Additionally, support and expand the use of clinical quality measures related to tobacco use screening and treatment to assess performance and incentivize care delivery.

Box 8.1 What can be done at the local, state, and federal levels to advance equitable enforcement of evidence-based tobacco prevention and control strategies?

- Reform or eliminate enforcement practices for violations of local or state sales or smokefree laws that target individual consumers, including youth, and prioritize policy enforcement efforts that focus on industry actors;
- Ensure that enforcement practices and penalties for violations of tobacco-free schools and similar policies are proportional to the alleged violations and leverage restorative justice and positive disciplinary alternatives for individuals instead of traditional enforcement mechanisms;
- Monitor unintended consequences of tobacco policy interventions, particularly for communities and population groups that are disproportionately affected by health inequities;
- Ensure that city planning prioritizes health equity by reducing the density of tobacco retailers and by affording spaces and places with equitable and comprehensive smokefree air protections (e.g., included as a condition of rezoning);
- Work with and respect community members as the experts on their own local conditions;
- Protect all people, regardless of location, by limiting exposure to marketing from the tobacco industry to the extent legally permissible;
- Respect tribal sovereignty and distinguish between ceremonial tobacco and commercial tobacco in policies and programmatic initiatives;
- Allow for self-determination and limit the use of preemption by higher levels of government, which can thwart local policies that have the potential to improve health equity and reduce tobacco-related health disparities; and
- Ensure that policy implementation and enforcement is accompanied by meaningful expansion, promotion, and access to cessation services.

- Expand Medicaid eligibility and enrollment and ensure comprehensive, barrier-free cessation coverage for all Medicaid enrollees. Support health plans, including Medicaid, in identifying enrollees who use tobacco products to facilitate promotion of and connection to cessation supports without stigma, penalty, or barriers to coverage access.
- Advance comprehensive regulatory policies at multiple levels rather than industry self-regulatory approaches. Limit policy exemptions that may lead to loopholes in or inequitable implementation of comprehensive policies.
- Identify and eliminate potential conflicts of interest when conducting, disseminating, and translating science that informs government-sponsored programs, initiatives, and regulatory actions. This can include relying on independent, rather than industry-sponsored, study findings when assessing the health impacts of novel tobacco products.

### What Public and Private Sector Funders and Foundations Can Do

- Fund and incentivize cross-cutting, multisectoral initiatives to address upstream structural and social determinants of health, including tobacco-related health equity as an intended outcome.
- Ensure equity in funding practices, including conceptualization, selection, and implementation. Ensure community voices and diverse partners are represented in decision making and that solutions address community-articulated problems, questions, and needs. Expand the investment of structural interventions and provide significant resources for capacity building to support structural changes.
- Supplant tobacco industry funding with funding to civil rights, religious, and community-serving organizations.
- Disincentivize acceptance of tobacco industry funds among applicants and awardees, including through conditions of disclosure and funding, to the extent permissible. Require funded initiatives to measure the impact on equity. This includes the impact related to commercial tobacco initiation, tobacco cessation, and exposure to secondhand tobacco smoke.
- Fund sustainable, community-based participatory research initiatives. Dedicate funds for meaningful dissemination of findings to community members.
- Divest endowments from tobacco companies.

### What Public Health Practitioners and Health Communicators and Educators Can Do

- Equitably implement CDC’s Best Practices for Comprehensive Tobacco Control Programs—2014 (CDC 2014), prioritizing populations that are not yet protected by evidence-based tobacco prevention and control strategies. This includes efforts to increase the price of tobacco products (including through excise taxes, minimum price policies, and elimination of discounts) and dedicate revenues to tobacco control; advance smokefree protections, including in multi-unit housing; implement evidence-based tobacco countermarketing campaigns; and promote barrier-free access to and utilization of tobacco cessation treatment.
- Distinguish between commercial and traditional tobacco and acknowledge and respect the positive meanings of traditional tobacco for American Indian people.
- Advance social, structural, and political strategies to remove barriers to tobacco-related health equity by working in partnership with communities most impacted by the harms of commercial tobacco (Table 8.3). Bolster accessibility and appropriateness of health communications and countermarketing efforts. This includes developing and disseminating culturally appropriate communication efforts to raise awareness and counter disinformation about commercial tobacco products, including the goals of interventions to advance tobacco-related health equity.
- Scale up culturally relevant, free, and accessible resources that support tobacco cessation and that feature diverse and intersectional population groups and their experiences. Develop community-informed cessation resources and interventions.
- Work with healthcare systems and organizations to support the integration of tobacco use screening and treatment into routine clinical care for all patients. This includes ensuring that all healthcare facilities, including behavioral healthcare settings, are tobacco-free.
- Enhance the timely identification and measurement of commercial tobacco-related health disparities and drivers of health inequities. This can include:
  – Routinely measuring and reporting disaggregated sociodemographic characteristics and drivers of social and structural inequity;
  – Collaborating with researchers to gather data to support further development of interventions; and
  – Conducting health equity impact assessments and equity-framed monitoring and evaluation to inform communications, research, surveillance, program, and policy efforts.

### What Healthcare Professionals and Healthcare Organizations Can Do

- Advance the accessibility and availability of cessation services to improve equity in treatment access and utilization. By acknowledging that healthcare is not accessed, experienced, and/or received equitably by all people and population groups, healthcare professionals and healthcare organizations can:
  – Integrate clinical screening and treatment for all commercial tobacco use (not just cigarettes) in all healthcare settings and with all patients;
  – Ensure that clinical protocols for tobacco use screening and treatment are patient-centered and facilitate the receipt of evidence-based cessation treatment;
  – Increase access to innovative, accessible, and culturally and linguistically appropriate cessation services, including in geographic areas where policy protections are uneven or do not exist;
  – Create and sustain linkages to community cessation services (e.g., state quitlines) to enhance referrals, data sharing, and patient follow-up in an effort to increase patient access to and engagement with cessation supports;
  – Evaluate care delivery and quality of care for specific population groups that are impacted by tobacco-related disparities;
  – Ensure that all healthcare settings, including behavioral healthcare settings, are tobacco-free, with no exceptions; and
  – Provide barrier-free, widely promoted coverage of all evidence-based cessation treatments by all types of health insurers.
- Enhance and extend meaningful collaboration and partnerships between healthcare institutions, community healthcare clinics, community-based cessation services, community health workers, and community members. This includes conducting clinical screening of all patients to assess the use of tobacco products, delivering clinical cessation services to those who screen positive, and referring patients to adjunct services that can support and extend clinical care.
- End bias in screening for tobacco use and delivering cessation treatment through systems change and training at all levels. Work with medical and healthcare professional associations, educational institutions, and continuing education vendors to eliminate bias that may impede clinical screening for tobacco product use and the timely and appropriate delivery of and referral to cessation treatment.
- Address social determinants of health by incorporating into healthcare interventions ways to attend to the social and structural drivers of tobacco-related health inequities. By acknowledging that social determinants of health impact health-related outcomes, healthcare professionals and healthcare organizations can:
  – Integrate the assessment of social determinants of health, such as housing and food insecurity, into routine clinical care;
  – Develop and implement systems to connect patients with unmet social needs to appropriate community resources and support; and
  – Evaluate the delivery of interventions to address social determinants of health, including interventions among specific population groups experiencing tobacco-related disparities.

### What Researchers and Research Institutions Can Do

- Lead with scientific integrity, using quality standards and practices that are grounded in equity. Researchers and research institutions that conduct and devise standard protocols for performing research, surveillance, and evaluation activities can:
  – Ensure the use of health equity principles and approaches in all phases of tobacco-related surveillance, research, and evaluation, including, but not limited to, design, implementation, data interpretation, and dissemination in oral and published reports and manuscripts;
  – Measure and report self-identified categories among youth and adults, sociodemographic constructs and other markers of disparity (e.g., disability, behavioral health conditions, and sexual orientation and gender identity), and social determinants of health and other drivers of commercial tobacco-related disparities; and
  – Use intersectional approaches to analyze and disseminate data that identify tobacco-related health inequities within and across population groups while acknowledging numerous facets of identity that exist and interact among individuals and groups.
- Advance community-based participatory research approaches that respect and acknowledge community strengths and inherent resources. For example, include communities as meaningful partners in all phases and stages of conducted research; ensure research engagements and partnerships are mutually beneficial, strengthen capacity, and create co-learning opportunities; implement sustainable plans for long-term commitment; and disseminate knowledge gained to and through all involved partners.
- Disaggregate data reporting and oversample disparate populations to foster greater understanding of tobacco-related health disparities.
- Go beyond estimating population-level results to include examinations of the effects of strategies for reducing disparities and advancing tobacco-related health equity.
- Measure the use of the full spectrum of commercial tobacco products and flavors, including menthol, along with the social determinants of their use. This includes measuring use and drivers of use pertaining to the varied landscape of tobacco products and flavors among diverse and intersectional population groups.
- Commit to strict implementation of conflict-of-interest policies, including those that prohibit participation in research involving or sponsored by the tobacco industry.

### What Businesses and Employers Can Do

- Implement equitable policies and practices that support and protect all members of the workforce. This can include implementing tobacco-free worksite policies that protect all workers across the workforce from exposure to secondhand tobacco smoke; offering living wages and healthcare insurance that includes comprehensive, barrier-free coverage of evidence-based smoking cessation resources; and divesting employer-sponsored retirement funds from the tobacco industry (CEO Cancer Gold Standard n.d.).
- Work independently and with other businesses to denormalize and disincentivize the sale of tobacco products. This can include not displaying tobacco product advertising, not selling tobacco products, and investing in companies that do not sell or advertise tobacco products.

### What Schools and Academic Institutions Can Do

- Reinforce campuses as places for learning by establishing tobacco-free campus policies and providing education about the harms of using tobacco products. Leverage restorative justice principles and include alternatives that are less punitive than traditional enforcement mechanisms (e.g., enrollment in or referral to tobacco education and/or cessation services rather than expulsion for using tobacco products).
- Offer, or provide connection to, evidence-based cessation services for faculty, staff, and students who need support quitting tobacco use.
- Reject funding by and engagement with the tobacco industry. Eliminate conflicts of interest in research, curricula, scholarship, employment, and infrastructure initiatives.
- Divest academic institution endowments from tobacco companies.
- Provide supportive infrastructure for community-based participatory research.

### What Communities Can Do

- Advance social, structural, and political strategies to remove barriers to tobacco-related health equity (Table 8.3).
- Identify and reject efforts by the tobacco industry to influence policymaking.
- Foster relationships and shared decision making among decision makers, funders, and community members who are most impacted by commercial tobacco. Respect community members as the experts in their own communities.
- Ensure that communities impacted most by tobacco-related health disparities participate in decisions about how resources are used and evaluated.

### What Individuals and Families Can Do

- Do not use commercial tobacco products. People who use tobacco products can plan a quit attempt that might include talking to a doctor or other healthcare professional, calling their state tobacco quitline at 1-800-QUIT-NOW, or visiting smokefree.gov for help quitting.
- Encourage friends, family members, and coworkers—including youth—to quit the use of tobacco products. Support them in getting help to quit through such resources as 1-800-QUIT-NOW and smokefree.gov.
- Be an ally and exemplify allyship in principle and practice.
- Acknowledge and remedy social injustices that result in tobacco-related health disparities.
- Hold leaders accountable for protecting the health of all people, including groups that are disproportionately burdened by tobacco-related health disparities, and for ensuring that policy enforcement focuses on the tobacco industry and tobacco retailers instead of focusing on individual consumers and frontline salesclerks.
- Identify and debunk misinformation about commercial tobacco products and tobacco prevention and control strategies.
- Support, reward, and recognize community-serving and civil rights organizations that reject the support of or donations from the tobacco industry.
- Support businesses—especially those serving low-resource communities—that do not sell tobacco products but instead offer consumer products that promote health and wellness.
- Share personal stories about the negative impacts of commercial tobacco use on families.

### What Everyone Can Do

- Collaborate to advance a commercial tobacco endgame with the goal of enabling all people to live a healthy life that is free from tobacco use and exposure and from tobacco-related disease, disability, and death.
- Work together and be accountable. Accountability includes aligning resources, stated commitments, and actions to advance health equity.
- Measure progress, reward successes, acknowledge and learn from mistakes, and deploy resources when shortcomings need to be addressed.

Now is the time to move beyond envisioning to realizing a society with equitable opportunities and conditions for all people to live a life free from tobacco use, exposure to tobacco and secondhand tobacco smoke, and death and disease caused by commercial tobacco use. Through our plans, objectives, and actions, together we can achieve tobacco-related health equity.

## References

Al-Shawaf M, Grooms K, Mahoney M, Buchanan Lunsford N, Lawrence Kittner D. Support for Policies to Prohibit the Sale of Menthol Cigarettes and All Tobacco Products Among Adults, 2023; <https://www.cdc.gov/pcd/issues/2023/22_0128.htm>; accessed: February 14, 2023.
Albarracin D, Romer D, Jones C, Hall Jamieson K, Jamieson P. Misleading claims about tobacco products in YouTube videos: experimental effects of misinformation on unhealthy attitudes. Journal of Medical Internet Research 2018;20(6):e229.29959113
Altria. 2020 recipients of charitable contributions from the Altria family of companies, n.d.; <https://s3.documentcloud.org/documents/21083533/2020-recipients-of-charitable-contributions-from-the-altria-family-of-companies.pdf>; accessed: July 26, 2022.
Altria Group I. Altria reports 2021 second-quarter and first-half results; narrows 2021 full-year earnings guidance, July 29, 2021; <https://investor.altria.com/press-releases/news-details/2021/Altria-Reports-2021-Second-Quarter-and-First-Half-Results-Narrows-2021-Full-Year-Earnings-Guidance/default.aspx>; accessed: July 25, 2022.
American Nonsmokers’ Rights Foundation. Chronological Table of U.S. Populations Protected by 100% Smokefree State or Local Laws (as of April 1, 2023), April 1, 2023; <https://no-smoke.org/wp-content/uploads/pdf/EffectivePopulationList.pdf>; accessed: May 18, 2023.
American Nonsmokers’ Rights Foundation. U.S. 100% Smokefree Laws in Non-Hospitality Workplaces AND Restaurants AND Bars (as of July 1, 2022), 2022; <https://no-smoke.org/wp-content/uploads/pdf/WRBLawsMap.pdf>; accessed: July 26, 2022.
Apelberg BJ, Feirman SP, Salazar E, Corey CG, Ambrose BK, Paredes A, Richman E, Verzi SJ, Vugrin ED, Brodsky NS, . Potential public health effects of reducing nicotine levels in cigarettes in the United States. New England Journal of Medicine 2018;378(18):1725–33.29543114
Bailey ZD, Krieger N, Agénor M, Graves J, Linos N, Bassett MT. Structural racism and health inequities in the USA: evidence and interventions. Lancet 2017;389(10077):1453–63.28402827
Barber S. Place matters: from health and health care disparities to equity and liberation. North Carolina Medical Journal 2020;81(3):173–6.32366625
Baumgaertner E, Stockton B, Lindsay R. How big tobacco used George Floyd and Eric Garner to stoke fear among Black smokers, Los Angeles Times, April 25, 2022; <https://www.latimes.com/world-nation/story/2022-04-25/inside-big-tobaccos-strategy-to-stoke-fear-among-black-smokers-facing-menthol-bans>; accessed: July 25, 2022.
Berman M. Synthetic nicotine: closing the regulatory gap. In: Creative Chemistry: Addressing Industry Evasion and Synthetic Nicotine [webinar], December 15, 2021; <https://www.publichealthlawcenter.org/webinar/creative-chemistry-addressing-industry-evasion-and-synthetic-nicotine>; accessed: April 7, 2023.
Briggs J, Vallone D. The tobacco industry’s renewed assault on science: a call for a united public health response. American Journal of Public Health 2022;112(3):388–90.35196043
British American Tobacco. 2021—a pivotal year delivered; buyback announced, February 11, 2022; <https://www.bat.com/group/sites/UK__9D9KCY.nsf/vwPagesWebLive/DOCBHNFN/$file/FY_2021_Announcement.pdf>; accessed: July 25, 2022.
British American Tobacco Company. Building the Enterprise of the Future: Annual Report and Form 20-F 2020, 2021; <https://www.bat.com/ar/2020/pdfs/BAT_AR20-F_2020_Governance.pdf>; accessed: September 12, 2022.
California Office of Environmental Health Hazard Assessment. The Proposition 65 list, n.d.; <https://oehha.ca.gov/proposition-65/proposition-65-list>; accessed: July 26, 2022.
Campaign for Tobacco-Free Kids. State Tobacco Prevention Spending vs. Tobacco Company Marketing, December 22, 2023; <https://www.tobaccofreekids.org/assets/content/what_we_do/state_local_issues/settlement/FY2023/5-State-Tobacco-Prevention-Spending-vs-Tobacco-Company-Marketing.pdf>; accessed: February 22, 2024.
Centers for Disease Control and Prevention. Best Practices for Comprehensive Tobacco Control Programs—2014. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2014; <https://www.cdc.gov/tobacco/stateandcommunity/guides/pdfs/2014/comprehensive.pdf>; accessed: July 26, 2017.
Centers for Disease Control and Prevention. Coverage for tobacco use cessation treatments, June 2, 2021a; <https://www.cdc.gov/tobacco/quit_smoking/cessation/coverage/index.htm>; accessed: July 25, 2022.
Centers for Disease Control and Prevention. Media statement from CDC Director Rochelle P. Walensky, MD, MPH, on racism and health, April 8, 2021b; <https://www.cdc.gov/media/releases/2021/s0408-racism-health.html>; accessed: July 25, 2022.
Centers for Disease Control and Prevention. Smokefree policies reduce smoking, November 30, 2021c; <https://www.cdc.gov/tobacco/secondhand-smoke/protection/reduce-smoking.htm>; accessed: February 11, 2023.
Centers for Disease Control and Prevention. Identifying and Eliminating Tobacco-Related Disparities: Key Outcome Indicators for Evaluating Comprehensive Tobacco Control Programs—2022. Atlanta (GA): Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2022a; <https://www.cdc.gov/tobacco/stateandcommunity/guides/pdfs/2022-KOI-Guide-508.pdf>; accessed: May 30, 2023.
Centers for Disease Control and Prevention. STATE System excise tax fact sheet, June 16, 2022b; <https://www.cdc.gov/statesystem/factsheets/excisetax/ExciseTax.html>; accessed: July 25, 2022.
Centers for Disease Control and Prevention. STATE System Medicaid coverage of tobacco cessation treatments fact sheet, August 5, 2022c; <https://www.cdc.gov/statesystem/factsheets/medicaid/Cessation.html>; accessed: October 3, 2022.
Centers for Disease Control and Prevention. STATE System preemption fact sheet, August 5, 2022d; <https://www.cdc.gov/statesystem/factsheets/preemption/Preemption.html>; accessed: September 12, 2022.
Centers for Disease Control and Prevention. STATE System smokefree indoor air fact sheet, May 10, 2022e; <https://www.cdc.gov/statesystem/factsheets/sfia/SmokeFreeIndoorAir.html#anchor_1562859220>; accessed: July 25, 2022.
Centers for Medicare & Medicaid Services. Accountable Health Communities (AHC) Model Evaluation: Second Evaluation Report, May 2023; <https://www.cms.gov/priorities/innovation/data-and-reports/2023/ahc-second-eval-rpt>; accessed: February 23, 2024.
Centers for Medicare & Medicaid Services. Redesigning Care Around the Social Determinants of Health: A Resource Guide and Introduction to the CMLN Social Determinants of Health Affinity Group, n.d.; <https://www.hhs.gov/guidance/sites/default/files/hhs-guidance-documents/CMLN%20Social%20Determinants%20of%20Health%20Relevance%20and%20Resources%20Guide.pdf>; accessed: August 23, 2023.
CEO Cancer Gold Standard. Tobacco free worksites, n.d.; <https://www.cancergoldstandard.org/best-practices/tobacco-free-worksites>; accessed: February 25, 2024.^*^
Ciurcanu A, Cerantola A. Japan Tobacco International making a mint by circumventing menthol cigarette ban, November 2, 2021; <https://www.occrp.org/en/investigations/japan-tobacco-international-making-a-mint-by-circumventing-menthol-cigarette-ban>; accessed: July 25, 2022.
D’Souza DC, Radhakrishnan R, Sherif M, Cortes-Briones J, Cahill J, Gupta S, Skosnik PD, Ranganathan M. Cannabinoids and psychosis. Current Pharmaceutical Design 2016;22(42):6380–91.27568729
Dankwa-Mullan I, Pérez-Stable EJ. Addressing health disparities is a place-based issue. American Journal of Public Health 2016;106(4):637–9.26959267
Davis S. Black Marketing Research—Findings & Recommended Actions to Date, June 9, 1978; <https://www.industrydocuments.ucsf.edu/docs/rpmd0113>; accessed: September 12, 2022.
Dewhirst T. ‘Beyond nicotine’ marketing strategies: Big Tobacco diversification into the vaping and cannabis product sectors. Tobacco Control 2021.
DiGiulio A, Jump Z, Babb S, Schecter A, Williams KS, Yembra D, Armour BS. State Medicaid coverage for tobacco cessation treatments and barriers to accessing treatments—United States, 2008–2018. Morbidity and Mortality Weekly Report 2020;69(6):155–60.32053583
European Network for Smoking and Tobacco Prevention. Ban on menthol cigarettes: European Union member states shall prohibit the placing on the market of tobacco products with a characterising flavour [editorial]. Tobacco Prevention & Cessation 2020;6:40.33083673
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Proposed rule, tobacco product standard for nicotine level of combusted cigarettes (21 CFR 1130), 83 Fed. Reg. 11818 (2018).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Proposed rule: tobacco product standard for characterizing flavors in cigars (21 CFR 1166), 87 Fed. Reg. 26396 (2022a).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Proposed rule: tobacco product standard for menthol in cigarettes, (21 CFR 1162), 87 Fed. Reg. 26454 (2022b).
Heley K, Popova L, Moran MB, Ben Taleb Z, Hart JL, Wackowski OA, Westling E, Smiley SL, Stanton CA. Targeted tobacco marketing in 2020: the case of #BlackLivesMatter. Tobacco Control 2023;32(4):530–3.34907090
Hendlin YH, Vora M, Elias J, Ling PM. Financial conflicts of interest and stance on tobacco harm reduction: a systematic review. American Journal of Public Health 2019;109(7):e1–e8.
Holmes CB, King BA, Babb SD. Stuck in neutral: stalled progress in statewide comprehensive smoke-free laws and cigarette excise taxes, United States, 2000–2014. Preventing Chronic Disease 2016;13:E80.27309417
Jacobus J, Tapert SF. Effects of cannabis on the adolescent brain. Current Pharmaceutical Design 2014;20(13): 2186–93.23829363
Johnson D. Biden’s delay in banning menthol cigarettes puts more Black lives at risk [opinion], December 18, 2023; <https://www.msnbc.com/opinion/msnbc-opinion/biden-menthol-cigarette-ban-delay-black-lives-risk-rcna129954>; accessed: February 23, 2024.
Johnston M. Newport Smokers. November 18, 1982. Philip Morris Records Collection. Bates No. 3990497084-3990497097. <https://www.industrydocuments.ucsf.edu/docs/fqnn0189>.
Jordt SE, Jabba SV, Silinski P, Berman ML. An electronic cigarette pod system delivering 6-methyl nicotine, a synthetic nicotine analog, marketed in the United States as “PMTA exempt”. medRxiv 2023:[Preprint]: 2023.11.21.23298778.
Kickbusch I, Allen L, Franz C. The commercial determinants of health. Lancet Global Health 2016;4(12): e895–e896.27855860
MAB. Discussion Paper Total Minority Marketing Plan. September 7, 1984. Brown & Williamson Records Collection. Bates No. 531000141-531000144. <https://www.industrydocuments.ucsf.edu/docs/xgbw0138>.
Malone RE. Justice, disparities and the tobacco endgame. Tobacco Control 2021;30(e2):e76–e77.34880116
Malone RE, McDaniel PA, Smith EA. Tobacco Control Endgames: Global Initiatives and Implications for the U.K., July 2014; <https://www.cancerresearchuk.org/sites/default/files/policy_july2014_fullendgame_report.pdf>; accessed: July 20, 2022.
Malone RE, Proctor RN. Prohibition no, abolition yes! Rethinking how we talk about ending the cigarette epidemic. Tobacco Control 2022;31(2):376–81.35241615
Marino S. Senate Bill 12 faces opposition from organizations and senators. Times West Virginian, March 7, 2021; <https://www.timeswv.com/news/west_virginia/senate-bill-12-faces-opposition-from-organizations-and-senators/article_d0ea3b1a-7ded-11eb-aa7e-bfacd8aa3489.html>; accessed: May 18, 2023.
Marynak K, Emery S, King BA. Nicotine pouch unit sales in the U.S. from 2016 to 2020—reply. JAMA: the Journal of the American Medical Association 2021;326(22): 2331.
McMenamin SB, Yoeun SW, Halpin HA. Affordable Care Act impact on Medicaid coverage of smoking-cessation treatments. American Journal of Preventive Medicine 2018;54(4):479–85.29433953
McMenamin SB, Yoeun SW, Wellman JP, Zhu SH. Implementation of a comprehensive tobacco-cessation policy in Medicaid managed care plans in California. American Journal of Preventive Medicine 2020;59(4): 593–6.32828584
Mills SD, McGruder CO, Yerger VB. The African American Tobacco Control Leadership Council: advocating for a menthol cigarette ban in San Francisco, California. Tobacco Control 2021;30(e2):e150–e153.33483378
Mills SD, Rosario C, Yerger VB, Kalb MD, Ribisl KM. Recommendations to advance equity in tobacco control. Tobacco Control 2022:tc–2022–057670.
Mixner D. [DBM Associates Report]. June 9, 1998. Tobacco Institute Records Collection. Bates No. TCAL0404793-TCAL0404801. <https://www.industrydocuments.ucsf.edu/docs/qpgy0103>.
Moir D, Rickert WS, Levasseur G, Larose Y, Maertens R, White P, Desjardins S. A comparison of mainstream and sidestream marijuana and tobacco cigarette smoke produced under two machine smoking conditions. Chemical Research in Toxicology 2008;21(2):494–502.18062674
National Academies of Sciences E, and Medicine. The Health Effects of Cannabis and Cannabinoids: Current State of Evidence and Recommendations for Research. Washington (DC): The National Academies Press, 2017.
National Institutes of Health. Community Partnerships to Advance Science for Society (ComPASS), 2022; <https://commonfund.nih.gov/compass>; accessed: December 15, 2022.
New York State, Department of State, Division of Corporations. Certificate of amended name from Foundation for a Smoke-free World, Inc. to Global Action to End Smoking, Inc. [corporation and business entity database], n.d.; <https://apps.dos.ny.gov/publicInquiry/>; accessed: February 23, 2024.
Nez Henderson P, Leischow S. Air Is Life: the Navajo Nation’s historic commercial tobacco ban, February 7, 2022; <https://www.cancer.gov/news-events/cancer-currents-blog/2022/navajo-nation-commercial-tobacco-ban>; accessed: July 25, 2022.
Organizing Committee for Assessing Meaningful Community Engagement in Health & Health Care Programs & Policies. Assessing meaningful community engagement: a conceptual model to advance health equity through transformed systems for health, February 14, 2022; <https://nam.edu/assessing-meaningful-community-engagement-a-conceptual-model-to-advance-health-equity-through-transformed-systems-for-health/>; accessed: July 26, 2022.
PennRutgers TCORS. Tobacco Industry Marketing (TIM) alert, May 13, 2022; <https://us5.campaign-archive.com/?u=9bedf525975b2e0d865d3fff5&id=93a9b150b7>; accessed: July 26, 2022.
Pisinger C, Godtfredsen N, Bender AM. A conflict of interest is strongly associated with tobacco industry-favourable results, indicating no harm of e-cigarettes. Preventive Medicine 2019;119:124–31.30576685
Powers M, Faden R. Social Justice: The Moral Foundations of Public Health and Health Policy. New York (NY): Oxford University Press, 2006.
Powers M, Faden R. Structural Injustice: Power, Advantage, and Human Rights. New York (NY): Oxford University Press, 2019.
Public Health Law Center. U.S. e-cigarette regulations—50-state review, 2022; <https://www.publichealthlawcenter.org/resources/us-e-cigarette-regulations-50-state-review>; accessed: July 9, 2022.
Public Health Law Center at Mitchell Hamline School of Law. R.J. Reynolds Tobacco Company et al. v. U.S. Food and Drug Administration et al. (2020), 2020; <https://www.publichealthlawcenter.org/litigation-tracker/rj-reynolds-tobacco-company-et-al-v-us-food-and-drug-administration-et-al-2020>; accessed: February 13, 2023.
Purpose Built Communities. How we work: prosperity starts with place, n.d.; <https://purposebuiltcommunities.org/how-we-work/>; accessed: May 22, 2023.
Raymond N. U.S. Supreme Court rejects challenge to California flavored tobacco ban, January 8, 2024; <https://www.reuters.com/legal/us-supreme-court-rejects-challenge-california-flavored-tobacco-ban-2024-01-08/>; accessed: February 23, 2024.
Reynolds American. Santa Fe Natural Tobacco Company Foundation, n.d.; <https://www.reynoldsamerican.com/santa-fe-foundation>; accessed: March 4, 2024.
Robeznieks A. Knocking down barriers to health equity, 2019; <https://www.ama-assn.org/delivering-care/patient-support-advocacy/knocking-down-barriers-health-equity>; accessed: February 11, 2023.
Satcher D, Higginbotham EJ. The public health approach to eliminating disparities in health. American Journal of Public Health 2008;98(9 Suppl):S8–S11.18687626
Schindler A. It Is Imperative that You Get Involved in the Political Process, Because You Can Rest Assured Those Who Oppose You Are Involved. 2000. R.J. Reynolds Records Collection. Bates No. 524227572-524227575. <https://www.industrydocuments.ucsf.edu/docs/sqdl0091>.
Shaw DM, Etter JF, Elger BS. Should academic journals publish e-cigarette research linked to tobacco companies? Addiction 2016;111(8):1328–32.26412439
Smith EA, Malone RE. An argument for phasing out sales of cigarettes. Tobacco Control 2020;29(6):703–8.31542777
SPREE BAR. SPREE BAR [home page], 2023; <https://web.archive.org/web/20231008033049/https://spreebar.com/>; accessed: March 4, 2024.
Stanford Research into the Impact of Tobacco Advertising. [Collection of advertisements by Kool non-menthol brand cigarettes], n.d.; <https://tobacco.stanford.edu/cigarettes/menthol-medicates/nonmenthol/#collection-29>; accessed: May 22, 2023.
Sticht JP. Four Leading Black Publishers from the National Newspaper Association Will Visit with Us on May 22, 1979. 1979. R.J. Reynolds Records Collection; Master Settlement Agreement Collection. Bates No. 501472252. <https://www.industrydocuments.ucsf.edu/tobacco/docs/#id=npxn0088>.
Substance Abuse and Mental Health Services Administration. Key Substance Use and Mental Health Indicators in the United States: Results from the 2019 National Survey on Drug Use and Health, 2020; <https://www.samhsa.gov/data/sites/default/files/reports/rpt29393/2019NSDUHFFRPDFWHTML/2019NSDUHFFR1PDFW090120.pdf>; accessed: July 25, 2022.
Substance Abuse and Mental Health Services Administration. Preventing Marijuana Use Among Youth. Rockville (MD): National Mental Health and Substance Use Policy Laboratory, Substance Abuse and Mental Health Services Administration, 2021. SAMHSA Publication No. PEP21-06-01-001.
Tan ASL, Bigman CA. Misinformation about commercial tobacco products on social media-implications and research opportunities for reducing tobacco-related health disparities. American Journal of Public Health 2020;110(Suppl 3):S281–S282.33001728
Tan ASL, Soneji S, Moran MB, Choi K. JUUL Labs’ sponsorship and the scientific integrity of vaping research. Lancet 2019;394(10196):366–8.31379323
Terry-McElrath YM, O’Malley PM, Johnston LD, Bray BC, Patrick ME, Schulenberg JE. Longitudinal patterns of marijuana use across ages 18–50 in a U.S. national sample: a descriptive examination of predictors and health correlates of repeated measures latent class membership. Drug and Alcohol Dependence 2017;171:70–83.28024188
The Bureau of Investigative Journalism. Pastor offered $250,000 to oppose menthol cigarette ban, August 25, 2022; <https://www.thebureauinvestigates.com/stories/2022-08-25/pastor-offered-250-000-to-oppose-menthol-cigarette-ban>; accessed: September 9, 2022.
The Network for Public Health Law. 50-State Legislative Law and Bill Survey: Summary of Enacted Laws and Pending Bills Limiting Public Health Authority: The Second Wave (Version Posted, June 1, 2022), 2022; <https://www.networkforphl.org/wp-content/uploads/2022/06/Summary-of-Enacted-Laws-and-Pending-Bills-Limiting-Public-Health-Authority-2.pdf>; accessed: May 18, 2023.
The White House. Executive order on advancing racial equity and support for underserved communities through the federal government, January 20, 2021; <https://www.whitehouse.gov/briefing-room/presidential-actions/2021/01/20/executive-order-advancing-racial-equity-and-support-for-underserved-communities-through-the-federal-government/?utm_source=link>; accessed: July 25, 2022.
The White House. Statement from President Biden on marijuana reform, October 6, 2022; <https://www.whitehouse.gov/briefing-room/statements-releases/2022/10/06/statement-from-president-biden-on-marijuana-reform/>; accessed: September 6, 2023.
Tobacco Tactics. Foundation for a Smoke-Free World, December 15, 2023; <https://tobaccotactics.org/article/foundation-for-a-smoke-free-world/>; accessed: February 22, 2024.
Tomar R, Beaumont J, Hsieh JCY. Evidence on the Carcinogenicity of Marijuana Smoke. Sacramento (CA): California Environmental Protection Agency, Reproductive and Cancer Hazard Assessment Branch, Office of Environmental Health Hazard Assessment, March 2009.
Trinkets & Trash. Earn points & dive into ATL’s evolving rap scene [Email], April 18, 2019; <https://trinketsandtrash.org/detail.php?artifactid=14518&page=1>; accessed: July 26, 2022.
Trinkets & Trash. [Instagram post by Swisher Sweets about inclusion, diversity, and transformation strategy], 2020a; <https://trinketsandtrash.org/detail.php?artifactid=15408&page=4>; accessed: July 26, 2022.
Trinkets & Trash. John Middleton Co. stands against systemic racism [Email], July 27, 2020b; <https://trinketsandtrash.org/detail.php?artifactid=15404&page=1>; accessed: September 12, 2022.
Trinkets & Trash. Stand up. Be heard. Say “no” to raising your taxes [Email], July 21, 2021; <https://trinketsandtrash.org/detail.php?artifactid=15560&page=1>; accessed: September 12, 2022.
Trinkets & Trash. Speak out against a ban on menthol cigarettes [Email], May 25, 2022; <https://trinketsandtrash.org/detail.php?artifactid=15658&page=1>; accessed: July 26, 2022.
Truth Initiative. Tobacco Nation: An Ongoing Crisis—Examining the Health and Policy Disparities of U.S. States with the Highest Smoking Rates, June 2019; <https://truthinitiative.org/sites/default/files/media/files/2019/06/Tobacco-Nation-An-Ongoing-Crisis.pdf>; accessed: July 26, 2022.
Truth Initiative. Flavored tobacco policy restrictions as of September 30, 2023, 2023; <https://truthinitiative.org/sites/default/files/media/files/2024/01/Flavored-tobacco-policy-restrictions-Sept.30.2023.pdf>; accessed: February 22, 2024.
U.S. Census Bureau. Quick facts: Manhattan Beach City and Beverly Hills City, California, n.d.; <https://www.census.gov/quickfacts/fact/table/manhattanbeachcitycalifornia,beverlyhillscitycalifornia/PST045221>; accessed: July 26, 2022.
U.S. Department of Health and Human Services. Tobacco Use Among U.S. Racial/Ethnic Minority Groups—African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1998.
U.S. Department of Health and Human Services. The Health Consequences of Smoking—50 Years of Progress: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2014.
U.S. Department of Health and Human Services. E-Cigarette Use Among Youth and Young Adults. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2016.
U.S. Department of Health and Human Services. Smoking Cessation. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2020.
U.S. Department of Health and Human Services. Confronting Health Misinformation: The U.S. Surgeon General’s Advisory on Building a Healthy Information Environment, 2021; <https://www.hhs.gov/sites/default/files/surgeon-general-misinformation-advisory.pdf>; accessed: July 26, 2022.
U.S. Food and Drug Administration. Section 916 of the Federal Food, Drug, and Cosmetic Act—Preservation of State and Local Authority [section (a)(1)], 2018; <https://www.fda.gov/tobacco-products/rules-regulations-and-guidance/section-916-federal-food-drug-and-cosmetic-act-preservation-state-and-local-authority>; accessed: July 19, 2022.
U.S. Food and Drug Administration. FDA announces plans for proposed rule to reduce addictiveness of cigarettes and other combusted tobacco products: potential rule would propose to establish a maximum level of nicotine in cigarettes with the goal of reducing youth use, addiction and death [FDA news release], June 21, 2022a; <https://www.fda.gov/news-events/press-announcements/fda-announces-plans-proposed-rule-reduce-addictiveness-cigarettes-and-other-combusted-tobacco>; accessed: May 22, 2023.
U.S. Food and Drug Administration. FDA proposes rules prohibiting menthol cigarettes and flavored cigars to prevent youth initiation, significantly reduce tobacco-related disease and death [FDA news release], April 28, 2022b; <https://www.fda.gov/news-events/press-announcements/fda-proposes-rules-prohibiting-menthol-cigarettes-and-flavored-cigars-prevent-youth-initiation>; accessed: May 22, 2023.
U.S. Food and Drug Administration. Requirements for products made with non-tobacco nicotine take effect April 14, April 13, 2022c; <https://www.fda.gov/tobacco-products/ctp-newsroom/requirements-products-made-non-tobacco-nicotine-take-effect-april-14>; accessed: July 25, 2022.
UNDO. UNDO [home page], n.d.; <https://www.undo.org/>; accessed: July 20, 2022.
University of California–Davis Health System. Heavy, persistent pot use linked to economic, social problems at midlife: study finds marijuana not “safer” than alcohol, March 23, 2016; <http://www.sciencedaily.com/releases/2016/03/160323082016.htm>; accessed: December 15, 2022.
Vagg R, Chapman S. Nicotine analogues: a review of tobacco industry research interests. Addiction 2005; 100(5):701–12.15847628
Wallerstein N, Muhammad M, Sanchez-Youngman S, Rodriguez Espinosa P, Avila M, Baker EA, Barnett S, Belone L, Golub M, Lucero J, . Power dynamics in community-based participatory research: a multiple-case study analysis of partnering contexts, histories, and practices. Health Education & Behavior 2019; 46(1 Suppl):19S–32S.31549557
West Virginia Department of Health and Human Resources. Tobacco use: West Virginia Healthy People 2000 midcourse review, 1995; <http://www.wvdhhr.org/bph/hp2000/tob.htm>; accessed: May 9, 2023.
Winebrenner JT. Special Effects for Special Markets. July 21, 1988. R.J. Reynolds Records Collection. Bates No. 507714729-507714731. <https://www.industrydocuments.ucsf.edu/docs/jtvl0094>.
World Health Organization. Tobacco Industry Interference with Tobacco Control, 2008; <https://www.who.int/publications/i/item/9789241597340>; accessed: December 15, 2022.
World Health Organization. The Health and Social Effects of Nonmedical Cannabis Use. Geneva (Switzerland): World Health Organization, 2016.
Zeller M. FDA on track to take actions to address tobacco-related health disparities, January 27, 2022; <https://www.fda.gov/news-events/fda-voices/fda-track-take-actions-address-tobacco-related-health-disparities>; accessed: July 25, 2002.

1 In 2023, the Foundation for a Smoke-Free World announced that its agreement with Philip Morris International was terminated after accepting a final grant of $122.5 million from Philip Morris International (Tobacco Tactics 2023). Additionally, in December 2023, the foundation changed its name to Global Action to End Smoking, Inc. (New York State, Department of State, Division of Corporations n.d.).

* URL was active on the access date shown in the reference entry but was no longer active when this Surgeon General’s report was released.