# Chapter 7 Promising Interventions to Reduce Tobacco-Related Health Disparities

## Introduction

A variety of approaches can be used to reduce tobacco-related health disparities in the United States. This chapter uses a socioecological perspective (consistent with Chapter 4) (McLeroy et al. 1988; National Cancer Institute [NCI] 2017b) to highlight opportunities to address such disparities on multiple levels, including (1) establishing policies at the federal, tribal, territorial, state, and local levels; (2) conducting mass media campaigns; (3) implementing interventions, policies, and practices in organizational and institutional settings; (4) applying interpersonal interventions; and (5) implementing individual interventions.

Many of the approaches discussed in this chapter build upon contributions from the NCI Tobacco Control Monograph 22, A Socioecological Approach to Addressing Tobacco-Related Health Disparities (NCI 2017b) (referred to hereafter as NCI Tobacco Control Monograph 22). Although many of these approaches historically have not focused specifically on addressing tobacco-related health disparities, their successful and equitable execution (i.e., such that resources are allocated to each person according to their needs in order to attain an equal outcome) could have a significant impact on reducing such disparities. Some of the approaches discussed in NCI Tobacco Control Monograph 22 and in this chapter are similar to provisions of the World Health Organization (WHO) Framework Convention on Tobacco Control (WHO 2003), the global tobacco control treaty to which the United States is a signatory but not currently a party.

This chapter does not summarize all possible approaches that could reduce tobacco-related health disparities. Tobacco control advocates and public health practitioners can also look to the WHO Framework Convention on Tobacco Control and other key policy documents and reports to identify additional existing and emerging strategies that could be implemented and evaluated to better understand their impact on addressing tobacco-related health disparities in U.S. communities. Furthermore, Chapter 8 discusses tobacco endgame proposals to advance tobacco-related health equity, as well as liberatory approaches designed to remove social, structural, political, and commercial barriers to tobacco-related health equity.

## Overview

Efforts to reduce commercial tobacco use and its related disparities range from establishing federal policies to implementing individually based interventions. After an overview of the literature review methods and an orientation to community-engaged research, chapter sections are organized as follows:

- The first section focuses on tobacco control policies and practices that could reduce tobacco-related health disparities, including implementing smokefree policies; regulating tobacco products, including reducing nicotine levels; eliminating flavored tobacco products; enacting policies to reduce the supply of and demand for tobacco, including regulating where retailers are located; and regulating tobacco pricing through taxation and other price-related strategies.
- The second section examines community-level programs that aim to reduce the prevalence of smoking, particularly among populations experiencing disparities. These include community-level resources for smoking cessation, specifically tobacco cessation quitlines, and activities to raise public awareness of the harms and health risks of tobacco product use and tobacco product emissions, particularly through media campaigns.
- The third section discusses institutional- and organizational-level policy approaches to reduce tobacco-related health disparities, including policies focused on tobacco use prevention and cessation among youth and young adults, as well as approaches involving healthcare systems (e.g., clinical settings, insurance plans) and worksites.
- The fourth section focuses on interpersonal-level interventions, such as smoking cessation interventions that involve a support person, to reduce tobacco-related health disparities.
- Finally, the fifth section highlights individual-level interventions to reduce tobacco-related health disparities.

Throughout this chapter, racial and ethnic groups; people who identify as lesbian, gay, bisexual, transgender, queer, or intersex (LGBTQI+); lower socioeconomic status (SES) groups; and other population groups with disproportionately high rates of tobacco use and incidence of tobacco-related morbidity and mortality are referred to as (a) priority populations or (b) groups disproportionately affected by tobacco-related health disparities.

## Literature Review Methods

Academic literature platforms (including PubMed, Web of Science, MEDLINE, Scopus, Embase, Google Scholar) were searched for studies on interventions and approaches relevant to tobacco product use and tobacco control in general, on specific areas of intervention, and on the impact of such approaches on tobacco-related health disparities. Although time periods of searches varied (as described in Table 7.1), searches generally focused on literature published between 2015 and 2021 because NCI Tobacco Control Monograph 22 (NCI 2017b) synthesized the tobacco control literature on interventions through approximately 2014. This chapter also reviews earlier, seminal tobacco control research. Literature summarized in NCI Tobacco Control Monograph 22 is referenced where appropriate. Specific search strategies for each section are described in Table 7.1.

Table 7.1 Search strategies used for this chapter

Topic | Search strategy
Tobacco control policies
Preemption | Time period: extending back to 2009 but focusing on literature published since 2012–December 31, 2021; Indexes: Google Scholar, PubMed; Search terms: (preemption, tobacco); Notes: Articles obtained from this search were further scrutinized for their relevance in identifying examples of recent impacts of preemption on tobacco control and tobacco-related health disparities.
Smokefree air policies | Time period: 2010–December 31, 2021; Indexes: PubMed, Web of Science, and Embase; Search terms: (“environmental smoke” OR “secondhand smoke”) OR (smokefree OR smoke-free) AND (regulat* OR polic* OR ban* OR restriction*).; Notes: Articles obtained from this search were further scrutinized for their relevance to smokefree air policies in the United States, with a particular focus on implications for tobacco-related health disparities. Accordingly, this search informed the subsequent approach, specifically focusing on contextual factors related to the implementation of smokefree air policies (e.g., political factors, regional differences, race and ethnicity), places in need of further attention with regard to the implementation of smokefree air policies (e.g., casinos, multi-unit housing, vehicles), and smokefree air policies covering new tobacco products.
Tobacco product regulation and prohibiting the sale of flavored tobacco products | Updated search time period: 2018–December 31, 2021; Indexes: PubMed, Web of Science, MEDLINE, Embase, and Google Scholar; Search terms: (tobacco OR cigar* OR nicotine) AND (regulat* OR ban OR banned OR restriction*; OR prohib* OR flavor* OR flavor*) AND (“food and drug” OR “FDA”); Initial search time period: 2010–December 31, 2021; Indexes: PubMed, Web of Science, MEDLINE, Embase, and Google Scholar; Search terms: (tobacco OR cigarette* OR smoking OR nicotine) AND (regulat* OR market* OR package* OR polic* OR ban* OR restriction* OR industry* OR flavor* OR flavor*); Notes: A narrower search using the revised search string was performed for articles published between 2018 and 2021. Articles obtained from this search were further scrutinized for their relevance to the regulation of tobacco products in the United States, with a particular focus on the implications for tobacco-related health disparities. Accordingly, this search informed the subsequent approach, which focused specifically on nicotine reductions, new tobacco products, and bans or sales restrictions on flavored tobacco products.
Tobacco retail policies and practices: Place based
Pharmacies | Time period: 2008–2020; Index: PubMed; Search terms: (pharmacy AND (tobacco OR cigarette) AND (policy OR law OR ban OR end OR restriction OR regulation OR licens*); Notes: Studies were considered for inclusion if they assessed the impact of tobacco-free pharmacies (actual or simulated) on the retail environment (e.g., density reduction) or on adult tobacco use, with a particular focus on the implications for tobacco-related health disparities.
Restricting sales near schools | Time period: 2008–December 31, 2021; Index: PubMed; Search terms: (school AND (tobacco OR cigarette) AND (retailer OR outlet OR store OR point-of-sale OR point of sale) AND (distance OR proximity OR location OR licens*); Notes: Studies were considered for inclusion if they examined compliance with a local policy, assessed the actual or simulated impact of the policy on the retail environment (e.g., density reduction), or assessed the policy impact on youth tobacco use, with a particular focus on the implications for tobacco-related health disparities.
Other tobacco reduction strategies among retailers | Time period: 2008–December 31, 2021; Index: PubMed; Search terms: (tobacco OR cigarette) AND (retailer OR outlet OR store OR point-of-sale OR point of sale) AND (distance OR proximity OR location OR density) AND (policy OR law OR ban OR end OR restriction OR regulation OR licens*).; Notes: Studies were considered for inclusion if they assessed the actual or simulated impact of the policy on the retail environment (e.g., density reduction), with a particular focus on the implications for tobacco-related health disparities.
Tobacco retail policies and practices: Product focused
Tobacco pricing strategies | Time period: From inception date of each search engine (index) to December 31, 2021; Indexes: PubMed, EconLit, Web of Science, Google Scholar, and SSRN (formerly Social Science Research Network); Search terms: (cigarette, cigar, cigarillo, “smokeless tobacco,” and e-cigarette/electronic cigarette/electronic nicotine delivery system/ENDS) and the keywords “price/pricing” or “tax”; Notes: Studies included in the review (a) examined the impact of tobacco pricing policies with a particular focus on implications for different population groups defined by socioeconomic status, age, gender, race and ethnicity, mental health disorder, and/or sexual orientation and (b) used rigorous quantitative methods to examine the actual behavioral changes attributable to changes in tobacco pricing policies. Studies were excluded if they were perspectives, commentaries, or something similar or if they examined only intermediate outcomes, such as attitudes, beliefs, knowledge, and perceptions.
Prohibiting the sale of flavored tobacco products | See above search strategy for tobacco product regulation and prohibiting the sale of flavored tobacco products
Community-level efforts and programs
State-provided cessation resources | Time period: 2010–December 31, 2021; Indexes: PubMed, Web of Science, and Google Scholar; Search terms: ((tobacco OR cigarette* OR smoking OR nicotine) AND (*phone)) OR (quitline*); Notes: Articles yielded from this search were further evaluated for relevance to quitline research in the United States, with a particular focus on implications for tobacco-related health disparities.
Mass media campaigns | Time period: 2009–December 31, 2021; Index: PubMed; Search terms: “mass media” [MeSH Terms] AND “United States” [MeSH Terms] AND smoking [MeSH Terms] AND (cessation, tobacco use [MeSH Terms]) OR “smoking prevention” [MeSH Terms]) AND campaign; Notes: Studies were considered for inclusion if they discussed targeted media campaigns or assessed the efficacy of media campaigns focusing on high-risk population groups. Additional articles were identified through further searches using the reference sections from relevant articles and searching for publications evaluating the impact of known media campaigns.
Organizational-level programs and interventions
School-based tobacco prevention programs | Time period: Inclusive up to December 31, 2021; Indexes: Google; Search terms: see notes below.; Notes: Selected literature was reviewed for relevancy to tobacco prevention and tobacco cessation curricula and programs in schools.
College-based settings | Time period: 2010–December 31, 2021; Indexes: PubMed, Web of Science, MEDLINE, Embase, and Google Scholar; Search terms: “(tobacco OR cigarette* OR smoking) AND (college* OR university* OR campus OR young adult* OR college student*) AND (polic* OR ban* OR restriction* OR smoke-free OR smokefree OR tobacco-free OR cessation OR prevention OR program OR intervention)”; Notes: Articles were considered for inclusion that (a) focused on U.S. colleges or universities and students and (b) provided results about the prevalence of campus tobacco control policies, changes in tobacco use behaviors in relation to campus tobacco control policy adoption or implementation, and/or behavioral outcomes from cessation interventions for young adults attending college. With regard to the latter, the search also included key articles that involved findings from intervention studies that focused on the general population of young adults in cases where substantial proportions of the young adults were also college students. In addition, the search included meta-analyses and systematic reviews that summarized historical data. Particular focus was given to studies with implications for addressing tobacco-related health disparities.
Healthcare systems interventions | Time period: January 2000–December 31, 2021; Indexes: PubMed, Ovid; Search terms: PubMed search terms were (“health care” OR “healthcare” OR “hospital” OR “primary care” OR “ambulatory” OR “insur*” OR “pharmacy” OR “pharmacist” OR “dental” OR “dentist” OR “physician” OR “medical provider” OR “quitline”) AND (“policy” OR “guideline*” OR “practice” OR “interven*” OR “treat” OR “treatment” OR “implement*” OR “clinic*” OR “advice” OR “advise” OR “assist*” OR “quit” OR “technol*” OR “health record” OR “system*” OR “pharmacol*” OR “medication” OR “medical” OR “coverage” OR “screen” OR “apply” OR “application”) AND (“tobacco” OR “cigar” OR “cigarette” OR “nicotine” OR “pipe” OR “smokeless tob*” OR “snuff” OR “snus” OR “chewing tob*”) AND (“health status” or “health disparity” or “disparity” OR “race” OR “racial” OR “ethnic*” OR “education” OR “income” OR “socioeconomic*” OR “SES” OR “Medicaid” OR “lesbian” OR “gay” OR “bisexual” OR “transgender” OR “queer” OR “sexual orientation” OR “gender” OR “minority” OR “blue collar” OR “working class” OR “disability” OR “low income”).; The search string for the Ovid database, which did not identify any new articles, was (race or racial or ethnic* or education or income or socioeconomic* or SES or lesbian or gay or bisexual or transgender or LGBT or queer or sexual orientation or gender or minority or blue collar or working class or service or disability or low income or disadvantage) AND tobacco use or tobacco or nicotine AND addiction or dependence AND treatment or intervention or guideline*.; Notes: Abstracts were reviewed, and the full-text article was retrieved if it described a tobacco cessation treatment intervention in a healthcare setting that addressed a disparate population. Reference lists from full-text articles were reviewed to identify any articles not captured in the search. Where several articles were summarized in a systematic review or meta-analysis article, the review findings are reported. Search terms in article titles or abstracts were related to healthcare organization policies or practices related to tobacco, and disparities or specific groups with disproportionate rates of tobacco.
Worksite-based interventions | Time period: 2009–December 31, 2021; Indexes: PubMed, Google Scholar; Search terms: see notes below.; Notes: Selected literature was reviewed for the following issues relevant to these themes: (1) health plan policies; (2) wage policies; (3) access to cessation resources; (4) financial incentives to encourage workers to quit tobacco use; (5) structural barriers to cessation treatment in the workplace; (6) employers and labor unions working together on tobacco-related initiatives to support employees; (7) comprehensive tobacco-free workplace policies; (8) psychosocial exposures, organizational factors, and occupational hazards in the workplace to reduce disparities in tobacco use; and (9) hiring policies based on tobacco use.
Interpersonallevel interventions
Household smokefree air policies | Time period: January 1, 2008–December 31, 2021; Index: PubMed; Search terms: smoke-free homes OR household smoking bans OR home smoking bans OR home smoking restrictions OR household smoking restrictions.; Notes: Systematic reviews of interventions or evaluation research studies were examined in full, with a particular focus on the implications for tobacco-related health disparities.
Interventions engaging social support | Time period: January 2013 to December 31, 2021; Indexes: MEDLINE (via PubMed) and Embase; Search terms: partner OR buddy OR social OR household OR family OR couple OR dyad OR pair OR interpersonal. The search terms were used in combination with the following topic-related terms in titles or abstracts: (tobacco OR cigarette OR smoking) AND (cessation OR treatment OR intervention OR program OR abstinence OR quit).
Individual-level interventions | Time period: 2008-December 31, 2021; Indexes: PubMed and Web of Science; Search terms: racial or ethnic group; Black or African American, Hispanic or Latino, Asian; low SES or low-income; lesbian, gay, bisexual, or transgender (LBGT); or sexual or gender minority. These search terms were combined with the terms: tobacco, tobacco cessation, smoking cessation, smoking cessation intervention, tobacco cessation treatment, quitting smoking, smoking abstinence, and smoking RCT.; Notes: This review focused on published studies of specific groups or those that compared cessation outcomes by population group. Inclusion criteria included adults who smoked, quasi-experimental or randomized controlled trials, single-arm interventions, and two kinds of cessation outcomes (self-reported or biochemically

## Community-Engaged Research

Studies with community engagement components are included when available in this chapter’s evidence reviews. Participatory action research, first described by social scientist Kurt Lewin in the 1940s (Lewin 1948; Adelman 1993), acknowledged and sought to address “social problems” by joining experimental scientific approaches with social action programs. Originating from these theoretical underpinnings, community-based participatory research (CBPR) represents a collection of approaches focused on understanding and acting to address social, structural, and environmental inequities through intentional collaborations with community members, organizational representatives, and researchers in all aspects and phases of research, including development, implementation, and translation (Israel et al. 2001).

CBPR approaches respect communities as units of identity, acknowledge and build upon community strengths and resources, foster opportunities for co-learning and capacity building, and respect and emphasize problems defined by communities (Israel et al. 2003). These approaches also ensure research and community partners mutually benefit, create and activate a sustainable process for developing and fostering community and research partnerships with the requirement of long-term commitment, and disseminate research findings to all stakeholders (Israel et al. 2003). Such approaches have been extended to the fields of social and organizational science, education, healthcare, and public health. Community-engaged research approaches, which include CBPR, give communities the flexibility to selectively engage in phases of interest, such as developing research questions, designing studies, and collecting data (National Institute of Environmental Health Sciences n.d.).

Community-engaged approaches have been utilized in public health and expanded to include assembling community–academic–practice partnerships to address social and structural inequities and reduce health disparities (Minkler et al. 2008; Hearod et al. 2019; Valdez et al. 2020). Initiatives that have meaningfully engaged communities show the importance of these collaboratives in realizing broader and sustained effects on health outcomes (Minkler et al. 2003; Freudenberg 2004; Nelson et al. 2008), including those related to preventing the initiation of commercial tobacco use and exposure to secondhand tobacco smoke and helping with tobacco cessation.

## Tobacco Control Policies

Tobacco control policies across all levels of government (federal, tribal, territorial, state, and local) have the potential to significantly reduce tobacco-related health disparities if all populations are equitably protected by policies intended to reduce commercial tobacco use and exposure.^1^ State and local governments have long exercised their authority to enact smokefree laws, impose tobacco taxes, restrict the sale and distribution of tobacco products, reduce the illicit trade of these products, and adopt other tobacco control policies, in addition to conducting programs to prevent tobacco use, running mass media campaigns, and providing access to aids for smoking cessation (Tobacco Control Legal Consortium 2009).

On June 22, 2009, the Family Smoking Prevention and Tobacco Control Act (Tobacco Control Act) (2009) was signed into law. This act amended the Federal Food, Drug, and Cosmetic Act of 1938 and gave the U.S. Food and Drug Administration (FDA) the primary federal authority to regulate the manufacturing, marketing, and distribution of tobacco products; enforce these regulations; support regulatory science; and educate the public about FDA’s regulatory actions and about the harms of tobacco products. To carry out these activities, the Tobacco Control Act created FDA’s Center for Tobacco Products, which is supported by user fees charged to domestic manufacturers and importers of certain types of tobacco products (FDA 2019, n.d.c).

The Tobacco Control Act did not authorize FDA to levy taxes on tobacco products, adopt smokefree regulations, raise the minimum legal sales age for tobacco products, or prohibit sales of any tobacco product by a specific category of retail store, including pharmacies. Importantly, this Act did not restrict—and, in fact, it affirmed—existing state, territorial, tribal, and local authority to enact a wide range of policies. These include smokefree policies, excise tax laws, and policies related to the sale and distribution of tobacco products, such as those that reduce tobacco retailer density or prohibit the sale of tobacco products (Tobacco Control Legal Consortium 2014a).

Despite robust evidence about the efficacy of many tobacco control interventions in reducing tobacco use in the general population, limited research analyzes their effects on reducing tobacco-related health disparities. This section focuses on preemption, smokefree policies, regulation of tobacco products, and place-based and product-focused strategies.

### Preemption

Preemption occurs when the action of a lower level of government is blocked or overridden by the authority of a higher level of government. For example, under federal preemption, a federal law or regulation can constrain the legal authority of state and local governments. In turn, under state preemption, a state law or regulation restricts the authority of local governments (Kang et al. 2020; Pomeranz and Silver 2020). Preemptive laws and policies may seem neutral but can produce immediate and cumulative discriminatory effects that create and amplify tobacco-related health disparities (Centers for Disease Control and Prevention [CDC] 2012b; Carr et al. 2020; Yang and Berg 2022). The problem typically arises when a robust state or local tobacco control policy is blocked on grounds that it is prohibited by the authority of a weaker or less effective federal or state policy.

Preemption is a major concern in the context of tobacco control, where state governments and, more frequently, local governments often lead in adopting effective measures to reduce tobacco use, tailoring their policies to address local conditions (U.S. Department of Health and Human Services [USDHHS] 2000, 2014; Crosbie and Schmidt 2020). By limiting the ability of communities to protect the health and safety of their residents, preemption can prevent local municipalities from implementing tobacco control policies that could reduce tobacco-related health disparities, the burden of tobacco-caused morbidity and mortality, and, in turn, healthcare expenditures.

Preemption can be express or implied. Express preemption arises when the law of a higher level of government explicitly precludes a lower level of government from acting (Public Health Law Center 2018c). If the law of a higher level of government neither explicitly prohibits, nor explicitly affirms the authority of a lower level of government to act, a court may find implied preemption in two circumstances. First, a court may find that the higher level of government intended to be the sole entity to regulate a field, known as field preemption. Second, a court may find that a law or regulation of a lower level of government conflicts with a law or regulation of the higher level of government in such a way that it is impossible to comply with the laws of both governments, which is known as conflict preemption (Public Health Law Center 2018c; Sykes and Vanatko 2019; Kang et al. 2020).

The tobacco industry has long argued for explicitly preemptive laws, which undermine, overturn, or prohibit state or local regulatory authority (Gorovitz et al. 1998; USDHHS 2000; Crosbie and Schmidt 2020). Tobacco industry documents have shown that by limiting local regulatory authority (and when possible state regulatory authority), tobacco companies can focus their resources on fewer legislative bodies and pursue weaker regulations (Siegel et al. 1997; Gorovitz et al. 1998; CDC 1999). When states and localities do adopt evidence-based tobacco control policies, tobacco companies have frequently filed lawsuits to keep them from being enforced on the grounds that they are preempted by federal and state laws (see Chapter 5).

Tobacco companies have argued that preemptive laws create more equitable and uniform business practices that are economically viable for the tobacco marketplace (Burris et al. 2018). Conversely, public health opposition to preemption in the tobacco control context is due to the observation that preemptive laws “can abrogate state or local authority to adopt innovative solutions to public health problems, eliminate the flexibility to respond to the needs of diverse communities, [and] undermine grassroots public health movements” (Pertschuk et al. 2013, p. 214; Mamudu et al. 2020). Thus, preemptive laws not only preclude state or local authority to act on a particular topic but also can affect collaborative efforts within a community to address broader issues. Preemption can hinder local efforts to educate and raise awareness, prevent exploration of policy solutions to best meet the needs of the community, limit opportunities to shift social norms, and impede the diffusion of strong public health laws (Crosbie and Schmidt 2020).

Many health inequities stem from adverse social determinants of health; political empowerment to change those conditions is necessary to reduce such inequities (WHO 2008; CDC n.d.a). The Institute of Medicine (IOM) (now the National Academy of Medicine) recommends that when regulating for the public’s health, federal and state governments should set minimum standards but “allow states and localities to further protect the health and safety of their inhabitants” (IOM 2011, pp. 50–51). One of the national health objectives for the Healthy People campaigns, including Healthy People 2030, has been to eliminate policies in states and territories that preempt local tobacco control policies (Office of Disease Prevention and Health Promotion n.d.).

#### Federal Preemption: Tobacco Control Act

Several provisions of the Tobacco Control Act (2009) address preemption. The act expressly preempts state, territorial, and local requirements that are different from, or add to, any FDA requirements related to “tobacco product standards, premarket review, adulteration, misbranding, labeling, registration, good manufacturing standards, or modified risk tobacco products.” However, a “preservation” clause specifies that nothing in the act should be construed to preempt any state, territorial, tribal or local measure other than those that are subject to the express preemption provision. The preservation clause effectively clarifies that preemption by the act cannot be implied; state and local measures are either expressly preempted by the act, or they are not preempted at all.

The Act also contains a “savings” clause that reaffirms that nothing in the express preemption provision limits state, territorial, tribal, and local authority to adopt and enforce requirements related to the sale, distribution, exposure to, access to, advertising and promotion of, or use of tobacco products by individuals of any age, among other actions. The preservation and savings clauses together protect state, territorial, tribal, and local authority to adopt and enforce certain tobacco control measures (Schroth 2020). Courts have looked to the language of the act’s preservation and savings clauses when upholding the authority of local governments to restrict the sale of flavored tobacco products (National Association of Tobacco Outlets, Inc. v. City of Providence, R.I. 2013; Independents Gas & Service Stations Associations Inc. v. City of Chicago 2015).

Taken together, these provisions serve to both preserve and limit state, territorial, tribal, and local authority, thereby allowing these governments to reduce the use of tobacco products and their consequent health effects, while furthering Congress’ stated purpose of giving FDA exclusive authority over a few specific areas. Congress stated in the Tobacco Control Act’s preamble that one of its purposes in enacting the law was to expand both federal and state authority to “address comprehensively the public health and societal problems caused by the use of tobacco products” (Tobacco Control Act 2009, p. 1777).

The act also expands the scope of state, territorial, and local authority concerning cigarette labeling and advertising. Specifically, the Tobacco Control Act eliminated a portion of the preemptive language in the Federal Cigarette Labeling and Advertising Act of 1965 and expressly granted state, territorial, and local governments the authority to ban or restrict the time, place, and manner (i.e., when, where, and how advertising may take place) of cigarette advertising or promotion—but not the content. However, the Federal Cigarette Labeling and Advertising Act continues to expressly preempt all other state and local measures related to cigarette advertising and promotion. The mere fact that a local cigarette advertising or cigarette promotion regulation is expressly protected from preemption by the preservation and savings clauses in the Tobacco Control Act will not necessarily protect the regulation from preemption under the Federal Cigarette Labeling and Advertising Act. Thus, a New York City requirement for cigarette retailers to display health warnings next to their registers or tobacco product displays was determined to be preempted, on grounds that it was not a restriction on the time, place, or manner of advertising and promoting cigarettes (94th St. Grocery Corp. v. N.Y.C. Board of Health 2012). In contrast, a municipal ban on cigarette coupons and multipack discounts was upheld on the grounds that it was a time, place, and manner restriction, and thus not subject to preemption by the Federal Cigarette Labeling and Advertising Act (National Association of Tobacco Outlets, Inc. v. City of Providence, R.I. 2013; Independents Gas & Service Stations Associations Inc. v. City of Chicago 2015).

#### State Preemption: Smokefree Laws and Youth Access to Tobacco Products

Preemption at the state level varies by state and topic. Although state laws can preempt a wide array of local tobacco control policies, much of the research that has documented tobacco industry efforts with respect to preemption has focused on smokefree laws and laws prohibiting youth access to tobacco products. For example, in the 1980s when local governments started to prohibit smoking in workplaces, restaurants, and bars, the tobacco industry responded by “implement[ing] a strategy of promoting preemptive state bills nationwide” (Gorovitz et al. 1998, p. 40).

By 2000, a total of 18 states had preempted local restrictions on smoking. Repealing preemptive state bills can be difficult (Crosbie and Schmidt 2020). By 2010, however, because of effective advocacy efforts and various legal actions, the number of states with such preemptive laws had fallen to 12, with states such as Illinois, Iowa, Nevada, New Jersey, Oregon, and South Carolina completely removing smokefree preemption through legislation or the courts (Centers for Disease Control and Prevention 2011a). Preemptive state laws have been “associated with fewer local ordinances restricting smoking [and] a reduced level of worker protection from secondhand smoke” (Mowery et al. 2012). A policy analysis published in 2016 found that 9 of 24 states that lacked comprehensive smokefree state laws also had no local smokefree laws; 8 of these 9 states preempted localities from passing smokefree laws (Tynan et al. 2016). These gaps in coverage contribute to disparities in protection from exposure to secondhand tobacco smoke (CDC 2012a). Disparities in protection can result in tobacco-related health disparities because even brief exposure to secondhand tobacco smoke can cause serious health problems (USDHHS 2006).

A policy analysis published in 2016 found that 9 of 24 states that lacked comprehensive smokefree state laws also had no local smokefree laws; 8 of these 9 states preempted localities from passing smokefree laws (Tynan et al. 2016). Among these states is Florida, where voters approved an amendment to the state’s preemption law to prohibit smoking in workplaces and restaurants, but not in bars, beginning in 2003 (CDC n.d.g). Because of preexisting preemptive language in Florida’s law, local communities have not been able to enact policies that would otherwise expand on the state law and prohibit smoking in bars in their communities (Tynan et al. 2016).

“When states enact substantive policy coupled with preemption, the law protects the population but does not allow for local variation to address additional community needs and freezes policy as reflective of the science and values at the time it was passed”

(Pomeranz 2020)

In the words of one former tobacco industry lobbyist, “the … tobacco companies’ first priority has always been to preempt the field” (Crawford 1995, p. 202). Among other efforts, the industry heavily promoted preemptive state laws throughout the 1990s that prohibited local governments from passing ordinances to restrict youth access to tobacco products (Siegel et al. 1997). As of 2010, 22 states had preemptive youth access laws in effect (Centers for Disease Control and Prevention 2011a), an increase from 2000 (Crosbie and Schmidt 2020). As of December 31, 2021, 31 states had statutory language expressly preempting local governments from enacting smokefree, tobacco retail licensing, and/or youth access laws (CDC 2022).

Industry groups have a documented history of disseminating model legislation and engaging trade associations to encourage the passage of preemptive laws (Pomeranz et al. 2019; TSET Health Promotion Research Center, University of Oklahoma Health Sciences 2020). Strategies used to enact preemptive laws at the state level include, among other tactics, adding preemptive language to bills addressing unrelated topics, adding preemptive language late in the legislative process without the opportunity for public debate, and titling preemptive bills in a way that obscures their substance (Pomeranz and Silver 2020). In addition to recent efforts by corporations, trade organizations, and others to limit local public health authority to protect the public from serious illness, injury, and death (Pomeranz and Silver 2020; Network for Public Health Law and National Association of County and City Health Officials 2021), events in Pennsylvania, Hawaii, Florida, and Ohio suggest that the tobacco industry continues to pursue preemption of local tobacco control laws specifically (Crawford 1995). For example,

- In 2018, after the Philadelphia City Council introduced a measure to prohibit the sale of flavored cigars and cigarillos, the state legislature adopted a last-minute provision as part of the state budget preempting the city from adopting any new ordinance “regarding or affecting the sale of tobacco products” (Pennsylvania General Assembly 2018) by tobacco retailers licensed under state law (Briggs 2018).
- Similarly, in 2018, Hawaii enacted a provision, added at the last minute to a bill to fund kidney dialysis centers, that preempts “[a]ll local ordinances or regulations that regulate the sale of cigarettes, tobacco products, and electronic smoking devices” (Hawaii State Legislature 2018; PR Newswire 2018; Kang et al. 2020).
- In 2021, the Florida legislature amended its tobacco control statutes, explaining that the “establishment of the minimum age for purchasing or possessing, and the regulation for the marketing, sale, or delivery of, tobacco products is preempted to the state” (The Florida Senate 2021). Public health groups projected that Florida’s 2021 preemptive law invalidated an estimated 192 local policies (American Lung Association 2021).
- In 2024, the Ohio legislature overrode the governor’s veto of a bill that preempts local sales laws for flavored tobacco products. The governor told reporters that “it is a big win for Big Tobacco. They’ve lobbied this. They’ve been all over this” (Fahmy 2024).

These examples suggest that the tobacco industry will continue to seek to block local regulations, thereby limiting communities’ ability to address tobacco-related health disparities.

#### Summary and Recommendations

State and local governments have been at the forefront of enacting tobacco control laws to reduce tobacco use and exposure to secondhand tobacco smoke. These efforts, when implemented equitably, can help address tobacco-related disparities, as will be discussed in subsequent sections. Innovations in tobacco control that effectively reduce the prevalence of tobacco use and exposure to secondhand tobacco smoke in a single jurisdiction can encourage other jurisdictions to follow suit and improve on the first jurisdiction’s action, building momentum for change and opportunities for grassroots education and organizing. The tobacco industry recognizes this potential and has long focused on influencing states to remove local authority, as well as on using federal law to restrict state and local authority.

Preemption stops innovative policy efforts at the local and state levels because opportunities to adopt policies that can reduce tobacco-related health disparities are removed when a higher level of government preempts the actions of lower levels of government (Pertschuk et al. 2013). Community engagement—and power—are necessary to achieve and accelerate progress toward the goal of health equity (National Academy of Medicine n.d.). Preemption can lead to the exclusion of minoritized populations and people with lower incomes in shaping local laws that could protect their health and that of their children “by limiting their voice and involvement in policy considerations” (Yang and Berg 2022). Preemption at the state and federal levels can pose a significant obstacle both to enacting and to enforcing effective policy measures to address tobacco-related health disparities.

Although the 2009 Tobacco Control Act expressly preempts state, territorial, and local requirements in a narrow set of areas, the act explicitly and broadly preserves state, territorial, tribal, and local authority with respect to adopting and enforcing requirements concerning the use, sales, distribution, marketing, and taxation of all tobacco products. For example, generally, a local jurisdiction may enact a law prohibiting the sale of some or all tobacco products, restricting sales to specific types of retail stores such as tobacco-only retailers, or requiring a minimum price for tobacco products. Preventing and repealing express preemption laws is essential to advancing policies to prevent and reduce tobacco use and exposure to secondhand tobacco smoke, including among groups experiencing tobacco-related disparities. Using this strategy to reduce tobacco-related health disparities aligns with the Healthy People 2030 tobacco use objective to eliminate policies in states and territories that preempt local tobacco control policies—an objective that reinforces the importance of preserving local authority to protect the public’s health.

Preemption is often described in academic or complex legal terms, and its scope sometimes becomes evident only through litigation. Thus, it can be hard to fully explain or anticipate the limiting effects of a specific preemptive law. For these reasons, additional research is needed to evaluate the effects of preemption on tobacco-related health disparities and determine the best methods for communicating those impacts to affected communities and decision makers.

### Smokefree Policies

There is no risk-free level of exposure to secondhand tobacco smoke (USDHHS 2006). Exposure to secondhand tobacco smoke causes a wide range of harmful effects, including stroke, coronary heart disease, lung cancer, and low birth weight, sudden infant death syndrome, impaired lung function, and lower respiratory disease in children (USDHHS 1986, 2006, 2014; Miller et al. 2007; Moritsugu 2007; IOM 2010; Tan and Glantz 2012; Chen et al. 2014; Glantz and Johnson 2014; Cao et al. 2015; Macacu et al. 2015; Hori et al. 2016). Exposure to secondhand tobacco smoke affects at least 20% of the U.S. population—with striking disparities across race and ethnicity and SES (Brody et al. 2021; Shastri et al. 2021) (see Chapter 2). Further, exposure to secondhand tobacco smoke causes tobacco-related diseases that resulted in approximately 19,500 deaths among adults in 2019 (see Chapter 6). This section discusses the evidence related to population-level smokefree policies in public places, workplaces, multi-unit housing, and vehicles. Smokefree rules adopted by individuals and households are discussed later in this chapter.

#### Comprehensive Smokefree Laws

After the publication of the 1964 Surgeon General’s report, advocates brought national attention to the issue of exposure to secondhand tobacco smoke (Hyland et al. 2012). While some advocates focused on exposure to secondhand tobacco smoke in public places, flight attendants played a key role in highlighting occupational disparities in such exposure. Their occupation disproportionately exposed them to tobacco smoke on planes, resulting in respiratory illnesses and deaths, including from lung cancer (Holm and Davis 2004; Pan et al. 2005; Hyland et al. 2012). These efforts prompted multiple federal authorities to examine the evidence on the harms of exposure to secondhand tobacco smoke and led to the enactment of laws in the 1970s that prohibited smoking in some public places and a 1973 rule requiring airlines to provide separate smoking and nonsmoking seating areas on commercial flights (Holm and Davis 2004; Hyland et al. 2012). Following decades of advocacy efforts by flight attendants, laws enacted by the U.S. Congress banned smoking on flights lasting 2 hours or less in 1988, on flights lasting 6 hours or less in 1990, and on all domestic and international flights in 2000 (Holm and Davis 2004). It took so long to establish such airline smoking restrictions in part because tobacco companies considered them a serious threat to the continued social acceptability of smoking and worked for decades to stave off such restrictions (Lopipero and Bero 2006).

Continued educational and advocacy efforts spurred by the overwhelming evidence regarding the harms of exposure to secondhand tobacco smoke have resulted in the enactment of comprehensive smokefree laws over the past two decades by some state and local governments. These laws prohibit smoking in all indoor areas of workplaces and public places, including hospitality establishments such as restaurants and bars (Gingiss et al. 2009; International Agency for Research on Cancer [IARC] 2009; CDC 2012a; Tynan et al. 2016) (Figure 7.1).

The implementation of comprehensive smokefree laws has been associated with decreased exposure to secondhand tobacco smoke (USDHHS 2006; IARC and WHO 2009; Hahn 2010; Homa et al. 2015; O’Donald et al. 2020). Moreover, robust evidence shows that the implementation of state- and community-level legislation mandating that indoor areas be smokefree changes social norms about the acceptability of smoking, prevents initiation of cigarette use, reduces cigarette consumption, increases quit attempts, reduces cardiovascular and respiratory diseases among people who do not smoke, and improves perinatal and child health (Tan and Glantz 2012; USDHHS 2014; Been et al. 2015; NCI and WHO 2016; Peelen et al. 2016; Tynan et al. 2016). Failure to fully and equitably adopt, implement, and enforce smokefree laws contributes to disparities in protection from exposure to secondhand tobacco smoke, including across racial and ethnic groups and among those of lower SES, which can increase existing health disparities (Bartosch and Pope 1999; Skeer et al. 2004; Tong et al. 2009; Ferketich et al. 2010; Gonzalez et al. 2013; Garrett et al. 2015; Huang et al. 2015; NCI 2017b; Hafez et al. 2019; Smith et al. 2020; Daley et al. 2021a).

Figure 7.1 Maps of 100% smokefree air laws, United States, 2000, 2005, 2010, and 2022

A series of maps depicting the change over time in the number of cities, counties, and states with 100% smokefree laws in non-hospitality workplaces, restaurants, and bars as of January 1, 2000; January 1, 2005; January 5, 2010; and July 1, 2022.While the number of policies consistently increased over this period, by mid-2022, states in the South still generally lacked comprehensive statewide smokefree laws.

A As of January 1, 2000

B As of January 1, 2005

C As of January 5, 2010

D As of July 1, 2022

Source: American Nonsmokers’ Rights Foundation (n.d.), with permission.

The tobacco industry continues to oppose comprehensive smokefree laws, often by arguing, despite strong evidence to the contrary, that smokefree laws harm businesses (NCI and WHO 2016). Rigorous empirical studies that used objective economic indicators, were conducted in multiple jurisdictions, and that used a variety of methodologies have found that smokefree laws do not have negative economic consequences for businesses, including restaurants and bars; a small positive effect was observed in some cases (USDHHS 2006; Hahn 2010; NCI and WHO 2016).

Smokefree laws have been a key contributor to declines in cigarette smoking in the United States (Hyland et al. 2009; Mills et al. 2009; Tauras et al. 2013; USDHHS 2014, 2020; Song et al. 2015; Hawkins et al. 2016; Dahne et al. 2020a). Overall, compliance with comprehensive smokefree laws is high and these laws have strong public support (NCI and WHO 2016). Comprehensive smokefree laws in the United States are also associated with an increased adoption of voluntary smokefree home rules by both people who smoke and people who do not smoke (Borland et al. 2006; Messer et al. 2008; Mills et al. 2009; Cheng et al. 2011, 2015; Guzman et al. 2012).

As of April 2022, 28 states, American Samoa, the Marshall Islands, Puerto Rico, the U.S. Virgin Islands, and Washington, D.C. had adopted comprehensive smokefree laws in workplaces, restaurants, and bars (American Nonsmokers’ Rights Foundation 2022a, c; CDC n.d.i). Historically, most policies within or among states have been adopted at the local level (NCI 2000; USDHHS 2014). As of July 2022, 62.5% of the U.S. population was protected by local or state laws requiring that workplaces, restaurants, and bars all be smokefree (American Nonsmokers’ Rights Foundation 2022b). This figure does not take into account the people who also are protected by comprehensive policies adopted by tribes, such as the Cheyenne River Sioux Tribe Smoke-free Air Act of 2010 and the Navajo Nation Air is Life Act of 2021 (Cheyenne River Sioux Tribe 2015; Navajo Nation Office of Legislative Services 2021; National Native Network n.d.) and others.

Comprehensive smokefree laws could benefit all people (Dinno and Glantz 2009; Hill et al. 2014; Tabuchi et al. 2018), yet many jurisdictions in the United States lack such laws. Within jurisdictions that do have such laws, enforcement varies. A systematic review of studies published from 1995 through 2013 examined the impact of population-level tobacco interventions and policies on disparities in tobacco-related outcomes (e.g., prevalence of smoking, exposure to secondhand tobacco smoke, cessation) between higher and lower SES groups (defined in the study as equity impact) in Australia, Canada, Europe, and the United States. The review concluded that 25 studies of voluntary, regional, or partial smokefree policies (i.e., policies that were not national in scope or that did not require all indoor areas to be smokefree) showed the potential of these policies to increase SES-related inequities. The review suggested that voluntary, regional, or partial smokefree policies are more likely to be equity-negative than to be comprehensive national smokefree laws. Of the 25 studies of voluntary, regional, or partial smokefree policies, 19 were equity-negative, 1 was equity-positive, 1 was neutral, and 4 were unclear. Of the 19 studies on comprehensive national smokefree laws, 6 were equity-negative, 2 were equity-positive, 9 were neutral, 1 was mixed, and 1 was unclear with regard to the impact on SES-related inequities (Brown et al. 2014). The authors suggested possible reasons for only two studies showing positive equity impacts with respect to other outcomes. These reasons include variation in time lags between policy implementation and smoking behavior changes resulting from changes to social norms among different SES groups and higher prevalence of smoking and exposure to secondhand tobacco smoke among lower SES groups before the policies were passed. More research is warranted to better understand the equity impacts of these policies across population groups.

A literature review of studies from 2000 through 2019 examined the role of comprehensive smokefree laws in reducing the prevalence of smoking (Hafez et al. 2019). With respect to disparities in tobacco use, the review found that smokefree laws are associated with a decline in smoking among adolescents, in general, as well as adolescents from higher SES families, that localities with a higher SES are more likely to pass comprehensive smokefree laws, and that Asian and Hispanic people were more likely than non-Hispanic African American people to live in jurisdictions with smokefree laws.

Based on their review, the authors recommended implementing comprehensive, rather than partial, smokefree laws throughout the United States to reduce smoking among population groups with a high smoking prevalence. This review also showed the importance of examining underlying assumptions related to the impact on health disparities of the presence or absence of policies intended to enhance or promote good health. The presence of a policy may reduce tobacco initiation and use among all population groups but may not necessarily reduce or eliminate inequities. Recognizing that a number of complex factors are associated with tobacco use, the authors note that comprehensive smokefree policies in public places and workplaces could further reduce tobacco-related health disparities if implemented with smokefree housing policies and with smoking cessation services, though further research is needed to assess the impact (Hafez et al. 2019).

##### Diffusion of Comprehensive Smokefree Laws

The passage of modern, comprehensive smokefree laws began in the 1990s at the local level. Most states that adopted such laws did so between 2000 and 2010 (CDC 2011b; USDHHS 2014; Milov 2019). After making progress in the early 2000s, adoption of smokefree laws stalled at the statewide level (Holmes et al. 2016; Tynan et al. 2016; American Nonsmokers’ Rights Foundation 2022b). While comprehensive statewide laws extended throughout much of the Pacific, Midwest, and Northeast regions, statewide laws lagged in the South and Southeast, leaving any protection from exposure to indoor secondhand tobacco smoke in these regions dependent primarily on local smokefree laws adopted by communities that were not preempted from doing so (Figure 7.1).

Both the coverage and passage of smokefree laws have varied by sociodemographic characteristics, which differ by region and state (Huang et al. 2015) and can change over time (Deverell et al. 2006; Huang et al. 2015). Research has found that (a) localities with people of higher SES are more likely to pass comprehensive smokefree laws (Bartosch and Pope 1999; Skeer et al. 2004; Deverell et al. 2006; Ferketich et al. 2010; Huang et al. 2015); (b) smaller, rural communities are less likely to adopt smokefree laws compared with larger, urban areas (York et al. 2008; Hahn et al. 2009; Ferketich et al. 2010); and (c) the correlates of smokefree legislation that has both broad coverage and adequate strength involve having a larger proportion of workers who live and work in the same locality (Huang et al. 2015) or in a neighboring locality with a strong smokefree regulation (Skeer et al. 2004). The following section examines geographic variability in smokefree protections for racial and ethnic population groups.

##### Race, Ethnicity, and Geographic Variability

In the United States, urban areas have tended to have more smokefree policies and offer more protection from exposure to secondhand tobacco smoke than rural areas (Hafez et al. 2019). Regional and state-level studies of Massachusetts (Skeer et al. 2004), Texas (Gingiss et al. 2009; Huang et al. 2015), and Kentucky (Huang et al. 2015) indicate that localities with a higher proportion of people from minoritized racial and ethnic groups are more likely to pass smokefree legislation or to have legislation with stronger smokefree protections, which may be because much of the early comprehensive smokefree legislation was passed in urban metropolitan areas with concentrated minoritized racial and ethnic groups (Gingiss et al. 2009; Huang et al. 2015). For example, from 2000 through 2009, Asian and Hispanic people residing in metropolitan coastal cities in the United States were more likely to live in an area with a comprehensive smokefree law than their counterparts residing in other regions.

Even so, states in the South lack comprehensive statewide smokefree laws (Figure 7.1). The exact number of comprehensive smokefree laws adopted by American Indian and Alaska Native tribes is not known, but many tribes have enacted smokefree policies to protect their members from exposure to secondhand commercial tobacco smoke (O’Donald et al. 2020; Navajo Nation Office of the President and Vice President and Office of the Speaker 2021; National Native Network n.d.). As discussed in Chapter 6, not all racial and ethnic groups have experienced similar reductions in mortality attributable to exposure to secondhand tobacco smoke, even in states where there are comprehensive smokefree laws. Full implementation of smokefree protections across the United States and tribal lands could advance tobacco-related health equity. Monitoring progress in reducing disparities is a priority.

#### Smokefree Policies in Specific Settings

Smokefree policies have been extended to a variety of settings other than indoor public spaces, including hospitals (Williams et al. 2009), inpatient psychiatric facilities (Lawn and Pols 2005), corrections facilities (Kauffman et al. 2008), multi-unit housing (Pizacani et al. 2011), and public housing for lower income residents (Winickoff et al. 2010; Federal Register 2016a). Smokefree policies in these settings protect patients and residents, staff, and visitors from exposure to secondhand tobacco smoke and can reduce smoking, particularly when combined with cessation services (Kennedy et al. 2015; Vijayaraghavan et al. 2016).

Smokefree policies in hospitals and other medical facilities also contribute to community norms about the unacceptability of smoking (Hurt et al. 1989; Stillman et al. 1990). Policy interventions such as through accreditation requirements, state regulations, or local laws may require hospitals or psychiatric facilities to be smokefree. These facilities often expand their policies to make their entire campuses (indoors and outdoors) smokefree or tobacco-free.

As of January 2023, more than 4,100 hospitals and medical centers^2^ have adopted campuswide smokefree policies (American Nonsmokers’ Rights Foundation 2023a). This tally does not include two national managed care organizations (Cigna Corp., Kaiser Permanente); a nonprofit organization providing clinical care, education, and research (Mayo Clinic); and a Catholic nonprofit health system (SSM Health Care), which have adopted campuswide smokefree policies extending to their respective facilities, campuses, and office buildings. However, an analysis of the 2016 National Mental Health Services Survey found that less than half of behavioral health treatment facilities (49% of mental health treatment facilities and 35% of substance use treatment facilities) reported having smokefree campuses (Marynak et al. 2018b). Historic disparities in accepted norms among providers about smoking among people with versus without behavioral health conditions may have contributed to the relatively low adoption rate of smokefree policies in behavioral health treatment facilities (Prochaska et al. 2017). Over time, however, the number of behavioral health facilities with smokefree policies has continued to rise along with awareness about disparities in tobacco use and smoking-related morbidity and mortality among people with behavioral health conditions (Prochaska et al. 2017). As of January 2023, more than 160 psychiatric facilities^3^ have adopted smokefree policies for their buildings, and about half of these also have policies that apply to their entire campuses (American Nonsmokers’ Rights Foundation 2023a). Additionally, as of July 1, 2023, 9 states had enacted laws or regulations requiring mental health facilities to have tobacco-free grounds and an additional 5 states had enacted partial prohibitions, while 10 states had enacted laws or regulations requiring tobacco-free grounds for substance use treatment facilities and an additional 4 states had enacted partial prohibitions (Public Health Law Center 2023b). Hospitals and medical and behavioral health facility settings tend to serve people who are disproportionately affected by tobacco use (Hafez et al. 2019). Extending smokefree laws and policies to entire campuses could contribute to reducing tobacco use and exposure to secondhand tobacco smoke among those experiencing tobacco-related health disparities.

##### Smokefree Casinos

Casinos are also important venues for smokefree policy efforts because workers and patrons in casinos are exposed to high levels of secondhand tobacco smoke (Babb et al. 2015). Historically, many casinos have allowed indoor smoking without restriction and some state and local laws have exempted casinos from smokefree policies. Studies of air quality in casinos and of biomarkers in casino workers and patrons show that smoking in casinos is a public health problem, as documented by dangerous levels of secondhand tobacco smoke in these venues and elevated levels of tobacco smoke biomarkers in the blood, urine, and saliva of casino employees and patrons who do not smoke (Babb et al. 2015). As noted in Chapter 2, tobacco use disparities exist among populations employed in the hospitality industry and in casinos.

Only a few studies have examined disparities in exposure to secondhand tobacco smoke among casino workers or patrons by their sociodemographic characteristics. One study of California residents who visited tribal-owned casinos showed that certain populations were more likely to have visited tribal casinos and were exposed to secondhand tobacco smoke because of the lack of comprehensive smokefree policies in tribal casinos (Timberlake et al. 2012). The populations in this study who were more likely to have visited a casino included people over the age of 50, non-Hispanic African American people, and Hispanic people (Timberlake et al. 2012). The evidence is well documented that people who spend extended amounts of time in environments where smoking occurs, such as casino employees, are at an increased health risk because of the high concentrations and cumulative effects of exposure to secondhand tobacco smoke (USDHHS 2006; Babb et al. 2015).

The tobacco industry routinely works through a “plurality of third-party voices,” including those of business owners and concerned citizens, to argue that tobacco control laws, including smokefree laws, will harm other businesses—for instance, from revenue loss (Dearlove et al. 2002; Ulucanlar et al. 2016, p. 6). However, numerous economic studies have found that smokefree laws do not adversely impact business revenue (USDHHS 2006; Hahn 2010). One of the arguments, that opponents of smokefree casinos make, is that casino patrons still have a substantially higher prevalence of smoking than the population as a whole, suggesting that the effects that smokefree laws have on other types of hospitality businesses (such as a positive or neutral effect on revenue) do not apply to casinos. Observational studies have shown that only a small proportion of casino patrons actively smoke (Klepeis et al. 2012), and although active smoking rates in casinos vary across studies (Repace 2004, 2009, 2011; Pritsos et al. 2008; Jiang 2011; Timberlake et al. 2012; Brokenleg et al. 2014; Klepeis et al. 2016; Zhou et al. 2016), most casino patrons smoke at a rate similar to that of the general public (Babb et al. 2015). Smokefree casinos are also popular with the general public. A recent cross-sectional survey of adults found that 75% of adults favored smokefree casinos, with similar favorability among respondents who visited casinos (75.1%), including those who visit casinos about once a year (74.1%), several times a year (75.3%), and at least once a month (74.2%) (Tynan et al. 2019).

A review of peer-reviewed studies on the impact of smokefree laws on casino revenue found conflicting results but largely suggested that smokefree laws have a minimal or nonsignificant impact on revenue. The studies also may not have accounted for potential cost savings, such as reduced employee healthcare costs, changes in employee productivity, decreased maintenance costs, or decreased fire and property insurance (Babb et al. 2015). As discussed in more detail by Babb and colleagues (2015) and Tauras and colleagues (2018), the impact of Delaware’s smokefree law on casino revenue was examined in multiple publications that found conflicting results (Glantz and Alamar 2005; Mandel et al. 2005; Alamar and Glantz 2006; Pakko 2006, 2008). Mandel and colleagues (2005), and then additional analyses by Glantz and Alamar (2005) and Alamar and Glantz (2006), found that the state smokefree law did not significantly affect revenue, while Pakko (2006, 2008) found a decline in revenue. Another study that estimated the impact of Delaware’s law on slot machines by Thalheimer and Ali (2008) found reduced demand for slot machines after the smokefree law took effect. However, two studies of Illinois’ smokefree law found that the statewide smokefree law had no significant effects on Illinois casino attendance or revenues (Harris et al. 2012; Tauras et al. 2018).

Studies of community engagement with American Indian and Alaska Native people regarding smokefree policies have indicated the need for policy champions from within the community; extensive engagement with stakeholders, including tribal leaders and tribal members; and, in the case of casinos, the involvement of management and engagement with casino patrons and employees (Jiang et al. 2011; Brokenleg et al. 2014; Blanchard et al. 2015; Nez Henderson et al. 2016). This approach was taken by members of the Navajo Nation, who worked for 13 years on a strategy to build support for a smokefree environment on tribal land, resulting in the adoption of a policy in November 2021 that prohibits use of commercial tobacco, electronic cigarettes (e-cigarettes), and smokeless tobacco in all workplaces and public places on tribal land, including in tribal casinos (Navajo Nation Office of Legislative Services 2021; Navajo Nation Office of the President and Vice President and Office of the Speaker 2021).

As of April 2022, 21 states, as well as Puerto Rico and the U.S. Virgin Islands, had implemented laws requiring state-regulated gambling facilities to be 100% smokefree (even if no facilities existed at the time); these states covered approximately half (49.8%) of the U.S. population (American Nonsmokers’ Rights Foundation 2022b). Many cities, such as New Orleans, have also implemented smokefree laws that apply to casinos and other gambling facilities (New Orleans Health Department 2015).

Allowing smoking in casinos continues to expose hundreds of thousands of employees in casinos and millions of casino visitors to the known health risks of secondhand tobacco smoke (Babb et al. 2015; Tynan et al. 2019). Employees at risk of exposure to secondhand tobacco smoke include not only dealers, but also other hospitality sector employees who work in casinos, including hotel, restaurant, and bar employees. Failure to protect employees in these settings risks exacerbating health disparities among casino and hospitality workers relative to workers who are protected by workplace smokefree policies. State, territorial, local, and tribal smokefree laws that apply to casinos would protect these employees as well as visitors from the health effects of secondhand tobacco smoke.

##### Smokefree Multi-Unit Housing Policies

People living in multi-unit housing are particularly susceptible to exposure to secondhand tobacco smoke. Tobacco smoke (consisting of gases, chemicals, and particulate matter) travels between living units through ventilation systems, cracks, and seams that naturally occur between units. It accumulates in units, including those inhabited by people who do not smoke or who have adopted smokefree rules for their units (King et al. 2013a; Homa et al. 2015; Driezen et al. 2020; Matt et al. 2020). Some population groups that experience tobacco-related health disparities also are disproportionately exposed to secondhand tobacco smoke because they live in multi-unit housing, which can further worsen disparities (see Chapter 4). Homes are the primary source of exposure to secondhand tobacco smoke for children (USDHHS 2006). Exposure to secondhand tobacco smoke in rental housing and in multi-unit housing is higher than in privately owned and single-family homes (Wilson et al. 2011; Homa et al. 2015; Farley et al. 2022).

At an institutional level, decisions about implementing smokefree policies in multi-unit housing have largely been left to the discretion of individual developers and property managers (Farley et al. 2015) except in jurisdictions where local ordinances prohibit smoking in multi-unit housing (American Nonsmokers’ Rights Foundation 2004; Public Health Law Center 2021b). But most local smokefree ordinances do not apply to multi-unit housing. As of April 2022, a total of 74 municipalities nationwide had laws that required smokefree multi-unit housing—all 74 were located in California (American Nonsmokers’ Rights Foundation 2022b, d).

Adopting smokefree multi-unit housing policies has been shown to reduce exposure to secondhand tobacco smoke among residents who do not smoke and can increase cessation intentions and attempts among residents who do smoke (Pizacani et al. 2012; Levy et al. 2015; MacNaughton et al. 2016; Hollar et al. 2017; Gentzke et al. 2018; Horn et al. 2021). The efficacy of smokefree policies in reducing exposure to secondhand tobacco smoke in multi-unit housing is largely dependent on how well the policies are implemented and enforced (Rokicki et al. 2016; Klassen et al. 2017; Anthony et al. 2019; Thorpe et al. 2020).

Providing cessation resources can aid implementation efforts of smokefree policies in multi-unit housing (U.S. Department of Housing and Urban Development [HUD] 2014); these policies may have a greater impact if exposure to secondhand tobacco smoke is eliminated in workplaces, public places, and other sources of exposure outside the home (Pizacani et al. 2012; Levy et al. 2015; Kingsbury and Reckinger 2016; Young et al. 2016; Anthony et al. 2019). These results suggest that smokefree multi-unit housing policies may be implemented more successfully if accompanied by communication strategies that ensure that residents understand the policies, the harm caused by exposure to secondhand tobacco smoke, and how smokefree policies reduce harm.

In January 2016, HUD mandated that all public housing agencies implement indoor smokefree policies within all their buildings by July 2018 (HUD 2016). Surveys of multi-unit housing residents living in urban and rural areas across the United States have found high levels of support for policies prohibiting smoking in public housing (Wilson et al. 2017; Wang et al. 2018a). In 2013, 91.3% of U.S. survey respondents with children who were living in multi-unit housing agreed that tenants have a right to live in a smokefree building (Wilson et al. 2017). Similarly, data from the 2016 Summer Styles web-based survey of U.S. adults revealed that 73.7% of adults surveyed favored smokefree public housing, including 69.6% of respondents living in multi-unit housing (Wang et al. 2018a). In that survey, 44.3% of respondents who currently smoked, 73.2% of respondents who had formerly smoked, and 80.4% of respondents who had never smoked were in favor of smokefree policies (Wang et al. 2018a). These findings suggest that most U.S. adults favor smokefree public housing.

The HUD rule does not cover other forms of publicly subsidized housing, such as the Housing Choice Vouchers Program, Section 8, mixed-finance developments, project-based rental assistance developments, or tribal housing. Many lower income residents who are not affected by the HUD rule remain exposed to secondhand tobacco smoke in their homes (Anastasiou et al. 2020). Owners and property management companies that oversee privately owned housing can voluntarily implement smokefree policies—and do so at higher rates for market-rate properties than for subsidized housing, despite strong preferences for smokefree policies among lower income residents of subsidized housing (Gentzke et al. 2018). A study by Patel and colleagues (2022) of adults 18–64 years of age found support for smokefree multi-unit housing policies among most people who identified as a member of a minoritized racial or ethnic group, especially those who identified as Hispanic. Support was strongest overall for those who thought that exposure to secondhand tobacco smoke was harmful. The authors noted that these findings demonstrate the promise of this intervention to reduce disparities among certain racial and ethnic groups as well as people with lower incomes.

Smokefree policies are more likely to be found in newer buildings, buildings that cater to higher income people, public housing buildings subject to the HUD rule, and buildings with few children (Stein et al. 2015; Snyder et al. 2016). Such findings indicate the need to further promote smokefree policies in lower income multi-unit housing not covered by the HUD rule and to consider how to better protect children in housing. Tribal communities can also adopt policies to prohibit commercial tobacco use in multi-unit or subsidized housing. Efforts may be more successful if they acknowledge and respect the use of sacred tobacco, focus communications on the fact that children in particular may benefit from smokefree policies (rather than focusing on drifting smoke, because tribal housing often consists of single-family homes), and obtain community-specific data to understand and communicate the scope of the issue (Public Health Law Center 2020).

The widespread adoption of smokefree public housing policies could protect populations that experience tobacco-related health disparities, such as people with lower incomes and people from certain racial and ethnic groups, and also protect people who continue to be exposed to secondhand tobacco smoke from their neighbors, despite making their own residential units smokefree (NCI 2017b). For example, although Hispanic residents in multi-unit housing reported being aware of and concerned about exposure to secondhand tobacco smoke, they experienced high levels of exposure to secondhand tobacco smoke, even when they had rules to make their own residential unit smokefree (Delgado-Rendón et al. 2017; Rendón et al. 2017).

##### Smokefree Laws for Personal Vehicles

In 2019, nearly one-quarter of U.S. middle and high school students reported being exposed to secondhand tobacco smoke in cars (Walton et al. 2020). Non-Hispanic Black and non-Hispanic White students had a higher prevalence of exposure to secondhand tobacco smoke in vehicles than other students (Walton et al. 2020). Although there is no risk-free level of exposure to secondhand tobacco smoke, studies have found that the gases and particulate matter in secondhand tobacco smoke in vehicles can reach high levels that are particularly harmful to children (Rees and Connolly 2006; Fortmann et al. 2010; Northrup et al. 2016; CDC n.d.j).

As of December 2022, nine states, Guam, the Northern Mariana Islands, and Puerto Rico had passed laws prohibiting smoking in personal vehicles when children or adolescents are present (CDC n.d.j). Smokefree vehicle laws have the potential to limit exposure to secondhand tobacco smoke among youth, foster tobacco-free norms, and support tobacco cessation, including among population groups that are more likely to experience tobacco-related health disparities. The evidence concerning the health impact of this strategy is mixed and evidence concerning the strategy’s impact on disparities is limited. For example, an evaluation of a smokefree vehicle law in Scotland found an association between the law and reduced asthma-related hospital admissions among preschool children, but no impact was seen on older children (Mackay et al. 2021). A study of laws prohibiting smoking in vehicles in Canada found that the prevalence of exposure to secondhand tobacco smoke remained high, even among young children (Azagba et al. 2019). The authors of these studies noted that there is little enforcement of these laws, which could reduce their impact. In several jurisdictions, suspected violation of these laws may not serve as the basis for stopping a vehicle (Public Health Law Center 2017); this provision may help prevent selective enforcement among specific population groups (ChangeLab Solutions 2020). Another study found that voluntary smokefree car rules among adults in Maine increased after passage of a statewide smokefree vehicle law (Murphy-Hoefer et al. 2014). Most smoking restrictions in vehicles are established through voluntary household rules (Rees and Connolly 2006), as discussed later in this chapter.

#### Smokefree Policies and Other Tobacco Products and Cannabis

Although e-cigarettes do not generate sidestream aerosol between puffs, the exhaled aerosol from the person using e-cigarettes, known as secondhand e-cigarette aerosol, can expose people around them to nicotine, particulate matter, heavy metals, and carcinogenic chemicals such as formaldehyde and acetaldehyde (Ballbè et al. 2014; Czogala et al. 2014; Goniewicz et al. 2014; Kosmider et al. 2014; USDHHS 2016; Gray et al. 2020; Son et al. 2020; Eshraghian and Al-Delaimy 2021). Additionally, among people who do not use each respective product, people who are exposed to secondhand e-cigarette aerosol have been found to have levels of serum cotinine that are similar to those who are exposed to secondhand tobacco smoke from cigarettes (Flouris et al. 2013). Factors such as the number of people using e-cigarettes and the accumulation of aerosol constituents in the space where the products are used can impact levels of exposure, even though the secondhand emission levels per puff may be much lower than for cigarettes (Li et al. 2020).

More evidence (both cross-sectional and longitudinal) is needed to better understand the health effects of exposure to toxicants present in e-cigarette aerosol. Evidence available to date clearly indicates that bystanders are exposed to and can absorb the toxicants exhaled by people who use e-cigarettes (USDHHS 2016). Some devices also look like cigarettes, and e-cigarette aerosol is visually indistinguishable from cigarette smoke under some conditions (WHO 2014; USDHHS 2016). These factors may interfere with social norms that discourage cigarette use. Collectively, this evidence has already contributed to the enactment of legislation to protect people who do not use e-cigarettes from this exposure by expanding existing smokefree laws to include e-cigarettes and by including e-cigarettes from the outset in new smokefree laws.

Although historically, e-cigarettes have not been covered by most smokefree laws because those laws were often established before the introduction of these products, in the last decade, several localities, states, tribes, and territories have included e-cigarettes in their comprehensive smokefree laws. The wording of individual smokefree laws, as well as how other laws in the jurisdiction define “tobacco products” or “smoking” or identify specific product types, often determine whether smokefree laws regulate the use of e-cigarettes (and other devices used for inhalation of tobacco products, such as heated tobacco products) or if the laws must be amended to explicitly prohibit use of all electronic or combusted tobacco products (Hardin 2011; Lempert et al. 2016; Public Health Law Center 2018b, 2022b; Tobacco Control Legal Consortium and Public Health and Tobacco Policy Center 2018). As of April 2021, 17 states and Puerto Rico prohibit e-cigarette use as a part of a comprehensive smokefree law and 1,103 municipalities prohibit e-cigarette use in 100% smokefree venues (American Nonsmokers’ Rights Foundation 2021; CDC n.d.h).

Another issue concerning smokefree laws is cannabis, which has been legalized by many states in the last decade, including for nonmedical use by adults 21 years of age and older. Secondhand cannabis smoke contains many of the same toxic and cancer-causing chemicals found in tobacco smoke, and some of those chemicals are found in higher amounts in secondhand cannabis smoke than in secondhand tobacco smoke (Moir et al. 2008; CDC n.d.d, n.d.e). More research is needed to understand the adverse health effects of exposure to secondhand cannabis smoke, including as compared to secondhand tobacco smoke (CDC n.d.f).

As states have legalized adult cannabis use, use in public places has generally been prohibited, including outdoors. Some states have begun to make certain exceptions for indoor cannabis use within their otherwise comprehensive smokefree laws. For example, Colorado allows for the use of cannabis in certain restaurants and Michigan allows for use in certain restaurants and bars, despite otherwise having comprehensive laws that prohibit tobacco use indoors (American Nonsmokers’ Rights Foundation 2022c). Allowing cannabis use indoors and making exceptions to otherwise comprehensive smokefree laws will undermine the progress that has been made over decades to protect people who do not smoke, particularly those who are employed in jobs in the hospitality sector, from exposure to secondhand tobacco smoke and could lead to health disparities. As states and communities consider whether use of cannabis in public places should be permitted as a part of legalization, protecting all populations from exposure to secondhand tobacco smoke, including exposure to cannabis smoke, in all indoor settings should remain a priority.

#### Summary and Recommendations

There is robust evidence concerning the efficacy of smokefree laws and evidence documenting disparities in smokefree protections. Comprehensive smokefree laws for all indoor areas of public places and workplaces, including casinos, would be expected to reduce tobacco-related health disparities in exposure to secondhand tobacco smoke if they are adopted, implemented, and enforced fully and equitably. Smokefree laws have eliminated exposure to secondhand tobacco smoke in these settings among people who do not smoke and have successfully contributed to lowering the overall prevalence of smoking. These laws have also been shown to lower the prevalence of smoking among some population groups, such as adolescents (Hafez et al. 2019); people who are incarcerated (Kennedy et al. 2015); and people in addiction treatment centers, homeless shelters, and public housing (Vijayaraghavan et al. 2016), resulting in an absolute change in smoking activity and reductions in exposure to secondhand tobacco smoke and leading in turn to a substantial public health benefit. Continued efforts are needed to implement and examine the impact of smokefree policies on smoking prevalence among groups that are disproportionately affected by tobacco-related health disparities.

Similarly, smokefree policies for multi-unit housing also would be expected to reduce exposure to secondhand tobacco smoke if equitably adopted, implemented, and enforced. Public health and housing organizations have partnered to identify options for preventing exposure to secondhand tobacco smoke in multi-unit housing while also maintaining housing stability (Public Health Law Center 2023a). Policies such as HUD’s rule mandating smokefree public housing properties are an important step toward reducing these disparities in exposure to secondhand tobacco smoke, but policies will have a greater equity impact if they reach more people (e.g., people living in lower income multi-unit housing not covered by the HUD rule) and if challenges with compliance are overcome.

The evidence is inadequate to infer that smokefree laws that prohibit smoking in personal vehicles when children or adolescents are present reduce disparities in exposure to secondhand tobacco smoke. However, this finding should not prevent tobacco control practitioners from working on interventions that encourage people to create their own rules prohibiting smoking in their cars.

Based on the evidence reviewed, the following interventions, particularly when combined, would be expected to further reduce exposure to secondhand tobacco smoke and reduce disparities in exposure to secondhand tobacco smoke and the prevalence of health effects attributable to secondhand tobacco smoke:

- Expansion and implementation of comprehensive smokefree air laws so that 100% of the U.S. population is covered;
- Comprehensive smokefree air laws that cover public places and places of employment and do not exempt gaming venues, such as casinos; and
- 100% smokefree air laws and policies in multi-unit housing, including all forms of subsidized housing.

When implementing these interventions, smokefree policies will be most protective if they cover all emissions (i.e., smoke, aerosol) from the full range of products, including e-cigarettes, cigars, waterpipe, and cannabis. It is important that policy protections are equitably enforced such that policies are implemented with fidelity and without discrimination against individuals, that their implementation is monitored and evaluated, and that continued steps be taken to identify population groups who are still exposed to secondhand tobacco smoke and to eliminate such exposure. Steps to advance equitable, nondiscriminatory enforcement of smokefree and other evidence-based tobacco prevention and control policies as described in Chapter 8, Box 8.1, may include

- Prioritizing enforcement efforts that focus on industry actors (e.g., manufacturers and retailers) and proprietors of restaurants, bars, and worksites, rather than individual consumers; and
- Ensuring that enforcement practices are proportional to the alleged violation and, if individuals are subject to enforcement action in addition to industry actors, leveraging restorative justice practices (including referral to optional tobacco cessation support services) (Tobacco Control Enforcement for Racial Equity 2021) and alternatives to punitive enforcement mechanisms.

It is important to continue to evaluate the impact of smokefree policies on disparities in tobacco use and tobacco-related disease.

### Regulation of Tobacco Products

With the passage of the Tobacco Control Act in 2009, FDA was given immediate primary federal regulatory authority with respect to the manufacturing, marketing, and distribution of cigarettes, cigarette tobacco, “roll your own” tobacco, and smokeless tobacco, as well as authority over any other tobacco products that FDA regulations later “deemed” to be subject to the Federal Food, Drug, and Cosmetic Act. In 2016, FDA issued a final rule exercising this “deeming” authority to extend to any product made or derived from tobacco that is intended for human consumption, including any component, part, or accessory (Federal Register 2016b; FDA 2016). In April 2022, through the Consolidated Appropriations Act (2022), Congress expanded FDA’s authority to include tobacco products containing nicotine from any source, including synthetic nicotine. As of August 2023, FDA’s deeming authority as it applies to premium cigars is the subject of litigation after the District Court of the District of Columbia vacated a portion of the deeming rule related to this product (Cigar Association of America. v. U.S. Food & Drug Administration 2023).

The Tobacco Control Act permits FDA to create a regulatory framework for scientifically informed decisions on a variety of issues, including but not limited to the three topics discussed in this section:

- Levels of nicotine in tobacco products;
- Introduction of new tobacco products in the U.S. marketplace; and
- Elimination of flavors in tobacco products.

When exercising its authority with respect to these three topics, FDA is required to consider whether its action is appropriate for the protection of public health. This requires an assessment of risks and benefits to the population as a whole, including people who use and do not use tobacco products. FDA must also assess the likely impact of the action on initiation and cessation of tobacco use. Assessing an action’s impact on tobacco-related health disparities is not explicitly mentioned in the Tobacco Control Act. Given known disparities in tobacco use, an action’s impact on tobacco-related disparities could be considered within the assessment of population-level risks and benefits.

There may be other regulatory opportunities to address tobacco-related health disparities beyond the three areas highlighted in this section, such as those described in NCI Tobacco Control Monograph 22 (NCI 2017b). For example, FDA issued a final rule in March 2020 requiring large pictorial and textual health warnings on cigarette packages and advertisements, after an earlier health warning rule was overturned by a federal appellate court in 2012 due to a tobacco industry lawsuit (Federal Register 2020). This latest rule, which has not yet been implemented because it is also being challenged in the courts by the tobacco industry, could address disparities in understanding of the risks associated with the use of cigarettes among those who do and do not smoke (Federal Register 2020). Because the pictorial warning requirement offers more robust access to health information, particularly among people who smoke, and because the messages’ reach may extend into the interpersonal networks of people who smoke, this final rule has the potential to help reduce disparities in both understanding related to the harms of smoking and intention to quit (IOM 2006; Thrasher et al. 2012; Cantrell et al. 2013; NCI 2017b; Ramanadhan et al. 2017).

#### Levels of Nicotine in Tobacco Products

In March 2018, FDA issued an advance notice of proposed rulemaking that specifically requested data and other information to inform a potential tobacco product standard to reduce nicotine levels in cigarettes to make them minimally addictive or nonaddictive, for the protection of public health (Federal Register 2018). FDA can establish nicotine levels for tobacco products, although it is prohibited by the Tobacco Control Act from reducing nicotine yields in tobacco products to zero.

Nicotine is powerfully addictive and plays a dominant role in sustaining tobacco use (USDHHS 2014; Apelberg et al. 2018). Reducing the nicotine levels in cigarettes to make them minimally addictive or nonaddictive would help prevent those who experiment with cigarettes from becoming dependent on nicotine, help prevent them from transitioning to regular use, and thus help protect them from tobacco-related death and disease (USDHHS 2014; Federal Register 2018). This strategy, especially when combined with education, behavioral support for quitting, and access to cessation medications, could also result in increased rates of intentions to quit, attempts to quit, and smoking cessation (Benowitz et al. 2015; Hatsukami et al. 2015; Apelberg et al. 2018), including among adolescents (Cassidy et al. 2018). The growing literature on the potential impacts of reduced-nicotine cigarettes, as described next, indicates that reducing nicotine levels in cigarettes to minimally addictive or nonaddictive levels will benefit public health.

A 2018 study modeled the potential population-level effects of a policy setting a maximum level of nicotine in cigarettes to make them minimally addictive and found that this strategy could lead to a substantial reduction in tobacco-related mortality (Apelberg et al. 2018). Specifically, this study estimated that an additional 5 million adults who smoke would quit smoking within a year after implementation of such a policy, and that the prevalence of smoking among adults would drop from 7.9% in the baseline scenario to 1.4% by the year 2060. It estimated that if the policy had been adopted in 2020, by 2060, it would have prevented 16 million people who otherwise would have initiated smoking from starting to smoke. In addition, the study estimated that the adoption of this policy in 2020 would prevent 2.8 million tobacco-related deaths by 2060 and 8.5 million deaths by 2100 (Apelberg et al. 2018).

This modeling study assumed that the policy would apply to combusted tobacco products that likely would be used as substitutes for cigarettes (such as “roll your own” tobacco, pipe tobacco, and nonpremium cigars), but would not apply to other tobacco products (such as premium cigars, water pipe or hookah, e-cigarettes, and smokeless tobacco). Further, it assumed that, based on prior studies, the policy was unlikely to result in a substantial increased demand for cigarettes with higher nicotine levels from illicit sources (Apelberg et al. 2018). Some studies surveyed people who smoked and found the possibility of illicit trade if nicotine levels in cigarettes were reduced to minimally addictive or nonaddictive levels (Hall et al. 2019b; Popova et al. 2019), and have outlined the potential benefits of education and enforcement tools available to federal, state, territorial, tribal, and local governments, such as encrypted tax stamps, a track and trace system, and licensing requirements for distributors (Hall et al. 2019b; Ribisl et al. 2019). A 2018 paper from FDA analyzing potential responses to FDA tobacco product standards, including a reduced-nicotine product standard for cigarettes, concluded that the development of illicit markets likely would be minimized due to several factors, including higher manufacturing costs, lower profits, and the threat of enforcement action and criminal prosecution associated with producing and selling illegal products (FDA 2018c).

As discussed, a product standard that reduces nicotine levels in cigarettes to minimally addictive or nonaddictive levels (reduced-nicotine-content cigarettes) is expected to have a strong effect on preventing smoking initiation and reducing cigarette consumption among people who currently smoke. A randomized, double-blind clinical trial conducted among people who smoked cigarettes intermittently (nondaily) found that adults who were randomized to very-low-nicotine-content cigarettes reduced their daily cigarette consumption by an average of 51% (an average decrease of 1.6 cigarettes per day from baseline), while adults randomized to normal-nicotine-content cigarettes had no significant change in number of cigarettes consumed per day (Shiffman et al. 2018). These treatment differences were not moderated by gender or by race and ethnicity. Other clinical trials that assessed the impact of using reduced-nicotine-content-cigarettes have shown a reduction in the number of cigarettes smoked per day among people who are Black or African American, who have mental health conditions (such as elevated depressive symptoms or affective disorders), who are of lower SES, who are women, who have opioid dependence, and who are pregnant (Table 7.2) (Tidey et al. 2018, 2022; Higgins et al. 2020; Krebs et al. 2021).

The effects of reduced-nicotine-content cigarettes among populations with multiple forms of disadvantage have also been explored. In a secondary analysis of three randomized clinical trials (RCTs), Higgins and colleagues (2021) investigated whether reduced-nicotine content cigarettes could benefit people experiencing intersectional disparities (described as “cumulative vulnerabilities” in the study, including but not limited to rural residence, substance use disorder, disability status, and poverty). The authors “saw little evidence that cumulative vulnerabilities moderate response to reduced-nicotine-content cigarettes, suggesting that a policy reducing nicotine content in cigarettes to minimally addictive levels could benefit even highly vulnerable smokers” (Higgins et al. 2021, p. 1). In a subsequent secondary analysis of the same parent trials, Higgins and colleagues (2022a) found some evidence that a nicotine content reduction policy could result in more smoking persistence, but not more cigarettes smoked per day, among those with greater versus lower levels of cumulative vulnerability.

Table 7.2 Studies of impact of policies reducing nicotine to minimally addictive or non-addictive levels on tobacco-related health disparities

Study | Design, population, and location | Primary outcome(s) | Results
Donny et al. (2015) | - Seven-group, double-blind, randomized clinical trial conducted at 10 sites between June 2013 and July 2014; - Participants were recruited through flyers, direct mailings, television and radio announcements, and other advertisements; - A total of 840 participants, 18 years of age or older who smoked ≥5 cigarettes per day and were not currently interested in quitting smoking; 780 participants completed the study; - Participants were randomly assigned to smoke cigarettes for 6 weeks, using either their usual brands of cigarettes (n = 118) or one of six types of investigational cigarettes of different nicotine content; cigarettes were provided free; - Nicotine content of tobacco in the investigational cigarettes varied:; – 15.8 mg/g (n = 119); – 5.2 mg/g (n = 122); – 2.4 mg/g (n = 119); – 1.3 mg/g (n = 119); – 0.4 mg/g (n = 119); – 0.4 mg/g high tar (n = 123) | - The primary outcome was the number of CPD at Week 6 and was assessed through an interactive voice-response system; - Other measures assessed: FTND, WISDM, MNWS, CES-D, QSU, TNE, cotinine, and NNAL | - During Week 6, the average number of CPD was lower for participants randomly assigned to cigarettes containing 2.4, 1.3, or 0.4 mg/g (16.5, 16.3, and 14.9 CPD, respectively) than it was for participants randomly assigned to their usual brands of cigarettes (22.2 CPD) or to cigarettes containing 15.8 mg/g (21.3 CPD); p <0.001); - Participants assigned to smoke cigarettes with 5.2 mg/g of nicotine smoked an average of 20.8 cigarettes per day, which did not differ significantly from the average number of CPD among those who smoked control cigarettes (15.8 mg/g); - Compared with control cigarettes, cigarettes with lower nicotine content reduced exposure to and dependence on nicotine, as well as reduced craving during abstinence from smoking, without significantly increasing the expired CO level or total puff volume, suggesting minimal compensation; - Adverse events were generally mild and similar among groups
Shiffman et al. (2018) | - Randomized, double-blind clinical trial; - Intent-to-treat analyses; - June 2015–July 2017; - Participants were recruited through the media, smoked cigarettes intermittently or non-daily, and were not planning to quit smoking in the next 3 months; - A total of 238 participants were randomized to two groups based on the level of nicotine content in cigarettes:; – VLNC cigarettes: 0.07 mg nicotine delivery (n = 118); – NNC cigarettes: 0.8 mg nicotine delivery (n = 120); - Baseline data were collected during a 2-week period in which participants smoked their own brands of cigarettes; - Outcomes were assessed biweekly, and cigarette butts were collected at Weeks 1–2, 3–4, 5–6, 7–8, and 9–10; - One study site: Pittsburgh, PA | - Compared changes in cigarette consumption—as measured by the number of CPD and number of days smoked— between baseline and the final 2 weeks of the trial (Weeks 9–10); - Three convergent methods assessed the number of CPD:; – Retroactive reports entered in calendar format; – Counts of cigarette butts returned; – Reports called into an interactive voice response system by participants each time they smoked; - Outcomes assessed by race and ethnicity and gender | - Loss to observation after randomization was similar in the two treatment arms; - In the intent-to-treat analyses, the VLNC group reduced consumption by 1.51 CPD more than the NNC group and reduced the number of days smoked by 17% more than the NNC group; - Mean changes in number of CPD:; – VLNC cigarettes: −1.6 CPD; – NNC cigarettes: −0.05 CPD; - Effects of VLNC cigarettes did not vary by gender or by race and ethnicity; - Number of CPD in the VLNC group declined steeply during the first 4 weeks (by 1.18 cigarettes per day) then leveled off; although the number of CPD differed between VLNC and NNC groups from Week 5 to Week 10, there were no group differences in CPD change over time from Week 5 to Week 10; - Results suggest that a policy mandating the use of VLNC cigarettes might reduce consumption without leading to quitting among people who smoke intermittently, as reductions in the number of CPD leveled off after 4 weeks
Denlinger-Apte et al. (2019) | - Secondary analysis of randomized clinical trial conducted by Hatsukami and colleagues (2018) to compare treatment effects of VLNC cigarettes and NNC cigarettes by menthol use status; - Adults who smoked and had no intention to quit smoking in the next 30 days; - After 2-week baseline phase, participants were randomly assigned for a 20-week condition to receive:; – VLNC cigarettes: nicotine = 0.4 mg/g (n = 503); – NNC cigarettes: nicotine = 15.5 mg/g (n = 249); - Participants received menthol or nonmenthol cigarettes, based on their preference:; – VLNC: menthol (n = 231) and nonmenthol (n = 272); – NNC: menthol (n = 115) and nonmenthol (n = 134); - Ten sites in the United States | - Mean total number of CPD (study plus non-study cigarettes) at Week 20; - CO-verified abstinence at Week 20 (CO ≤5 ppm; for the intent-to-treat analysis missing samples were imputed as non-abstinent [CO >5 ppm], whereas the per-protocol analysis included only participants with CO samples at Week 20); - Any cigarette-free days during the 20-week trial (yes or no); - Mean number of cigarette-free days during the 20-week trial | - Compared with those who smoked nonmenthol cigarettes at baseline (n = 406; all p <0.05), participants who smoked menthol cigarettes (n = 346) reported smoking fewer numbers of CPD (14.9 vs. 19.2) and having lower levels of TNE (52.8 vs. 71.6 nmol/mg) and CO (17.7 vs. 20.5 ppm); - At Week 20, significant interactions indicated that those who smoked menthol cigarettes (a) had smaller treatment effects than those who smoked nonmenthol cigarettes for number of CPD (−6.4 vs. −9.3), TNE (ratio of geometric means = 0.22 vs. 0.10), and CEMA (ratio = 0.56 vs. 0.37) (all p<0.05) and (b) trended toward a smaller treatment effect for CO (−4.5 vs. −7.3 ppm, p = 0.06); - ORs for abstinence at Week 20 were significantly lower for people in the menthol VLNC group than for those in the nonmenthol VLNC group (intent-to-treat OR = 1.88 vs. 9.11, p = 0.02 for the interaction)
Shiffman et al. (2019) | - 12-week double-blind randomized clinical trial; - Participants were adults, 18 years of age or older, who were recruited via a variety of media, reported smoking nondaily for at least 1 year or at any rate for at least 3 years, and were not seeking to quit smoking in the next 3 months; - People who smoked intermittently were randomized to two groups:; – VLNC cigarettes: 0.07 mg nicotine delivery (n = 118); – NNC cigarettes: 0.8 mg nicotine delivery (n = 120); - Multiple measures of dependence (FTND, NDSS, WISDM, and HONC) were assessed at baseline and 2, 6, and 10 weeks after randomization; - Pittsburgh, PA | - A principal component factor score captured common variance among the measures that were used to assess dependence; - Three convergent methods assessed the number of CPD | - People who smoked intermittently and switched to VLNC cigarettes reduced their dependence on nicotine on all measures, except WISDM Secondary Dependence Motives and HONC; - The reductions in dependence appear to be secondary to effects on cigarette consumption and do not appear to be an independent predictor or cause of reduced cigarette consumption
Tidey et al. (2019) | - Randomized, double-blind trial; - Data collected from November 2014 to September 2017:; – 2-week baseline period; – 6-week intervention period; – 1-week abstinence period; - Intent-to-treat analyses; - Adults, 18–70 years of age, who had serious mental illness (schizophrenia, schizoaffective disorder, or bipolar disorder), smoked ≥10 cigarettes per day, and were not seeking treatment for smoking or thinking about quitting; - A total of 58 participants were randomized to two conditions:; – VLNC: nicotine = 0.4 mg/g (n = 30); – NNC: nicotine = 15.8 mg/g (n = 28); - Providence, Rhode Island | - Primary outcome was total number of CPD (study plus non-study cigarettes) at Week 6, as measured by interactive voice response and timeline follow-back interviews; - Other behavioral and physiological measures: breath CO, TNE, and NNAL; - Questionnaires and assessments of psychiatric symptoms: FTCD, QSU, MNWS, modified CES, PANAS, PANSS, SANS, CES-D, Calgary Depression Scale for Schizophrenia, BPRS, AIMS, Simpson-Angus Scale, and BARS | - In total, 87% (n = 26) of participants in the VLNC group and 89% (n = 25) of those in the NNC group completed interactive voice responses through Week 6; 80% (n = 24) of participants in the VLNC group and 89% (n = 25) of those in the NNC group completed responses at the Week 6 in-person session; - Adjusted regression analyses indicated that participants in the VLNC condition smoked fewer total cigarettes per day (mean difference: −4.23 CPD, p = 0.047) and fewer study cigarettes per day (mean difference: −9.96 CPD, p<0.001) at Week 6 than did participants in the NNC condition; - CO levels (p <0.05) and QSU scores (p <0.05) were lower among participants in the VLNC group than they were among participants in the NNC group; - Participants in the VLNC group reported lower satisfaction, psychological reward, enjoyment, and a reduction in cravings than did participants in the NNC group; - No significant differences were observed between conditions at Week 6 for TNE, NNAL, FTCD, MNWS, and PANAS scores and for most measures of psychiatric symptoms, with exception of the Simson-Angus scale, for which scores were lower for the VLNC group than they were for the NNC group; - During the abstinence period, the median lapse to first cigarette was 2 days in the VLNC group and 1.5 days in the NNC group, but this difference was not statistically significant
Higgins et al. (2020) | - Describes three randomized clinical trials performed at the University of Vermont, Brown University, and Johns Hopkins University from October 2016 to September 2019; - A total of 775 participants who smoked cigarettes daily, had psychiatric disorders, or experienced socioeconomic disadvantage, including:; – People with affective disorders, exemplifying people who smoke with mental illness (n = 258); – People with opioid use disorder, exemplifying people who smoke with substance use disorders (n = 260); – Women with a high school education or less, exemplifying women who smoke and experience socioeconomic disadvantage (n = 257); - Participants were randomized to receive 12 weeks of exposure to study cigarettes:; – VLNC cigarettes: nicotine = 0.4 mg/g (n = 286); – LNC cigarettes: nicotine = 2.4 mg/g (n = 235); – Control cigarettes: nicotine = 15.8 mg/g (n = 286) | - Examined whether VLNC cigarettes decreased smoking rates and severity of nicotine dependence; - The primary outcome was between-group differences in mean total number of CPD (study and non-study cigarettes) during Week 12; - Secondary outcomes included number of CPD for study and nonstudy cigarettes and severity of nicotine dependence across weeks analyzed using analysis of covariance, random coefficients growth modeling, or repeated measures analysis of variance | - Participants randomized to the VLNC group had decreased mean (SEM) total number of CPD during Week 12 across populations (Cohen d = 0.61; p <0.001); - At Week 12, mean (SEM) number of CPD decreased to 17.96 (0.98) in the VLNC group and to 19.53 (1.07) in the LNC group, both of which differed significantly from the mean in the control group, which was 25.08 (1.08); - Compared with participants in the control group, the number of CPD decreased significantly among participants in the VLNC group (adjusted mean difference = −7.54 [95% CI, −9.51 to −5.57]) and those in the LNC group (adjusted mean difference = −5.33 [95% CI, −7.41 to −3.26]); the change was not significant between the VLNC and LNC groups; - Across the populations groups studied (those with affective disorders, opioid use disorder, and women with socioeconomic disadvantage), the number of nonstudy CPD was greater at lower nicotine doses (0.4 mg/g and 2.4 mg/g) than at the highest nicotine dose (15.8 mg/g); - Among people who smoked in the VLNC group, those with opioid use disorder smoked more and evidenced a steeper decreasing trend across weeks (weekly change = −4.42 [95% CI, −5.38 to −3.46] × study week) than did people with affective disorders (weekly change = −0.90 [95% CI, −1.81 to 0.01] × study week) or women with socioeconomic disadvantage (weekly change = −2.02 [95% CI, −2.99 to −1.04] × study week)
Carroll et al. (2021) | - Secondary analysis of a randomized clinical trial (n = 1,250); - Examined optimal approaches to nicotine reduction— which depended on the education level, gender, or race of people who smoked—and whether the optimal approach differentially benefited people who smoked based on their education level, gender, or race; - Analysis compared immediate and gradual reductions in nicotine from 15.5 to 0.4 mg/g; - People in the control group provided cigarettes with 15.5 mg/g nicotine | - Outcomes included number of CPD and CO, TNE, NNAL, PheT, and CEMA; - Data were analyzed as the area under the curve | - Regardless of education level, gender, and race, CPD, CO, TNE, NNAL, PheT, and CEMA were lower in people in the immediate nicotine reduction group than in those in the gradual nicotine reduction group; - Regardless of education level, gender, and race, outcomes were lower for those in the immediate nicotine reduction group than among those in the control group; however, the magnitude of the effect for TNE varied by race; - The geometric mean of the area under the curve of TNE was 49% lower in Black participants and 61% lower in White participants in the immediate nicotine reduction group than it was among their counterparts in the control group (p = 0.047); - Immediately reducing nicotine in cigarettes has the potential to benefit people who smoke regardless of education level, gender, and race
Higgins et al. (2021) | - Secondary analysis of three 12-week randomized clinical trials examining research cigarettes with different levels of nicotine content (0.4, 2.4, 15.8 mg/g) (Higgins et al. 2020); - Investigate the role of cumulative vulnerabilities in moderating responses to nicotine levels; - Analysis examined whether the risk of smoking increases in a summative manner corresponding with the number of co-occurring vulnerabilities (cumulative vulnerability); - Participants (n = 775) were categorized as having low (0–1), moderate (2–3), or high (4–7) cumulative vulnerabilities; - Vulnerabilities included rural residence, current substance use disorder, current affective disorder, low level of educational attainment, poverty, unemployment, and physical disability | - The primary outcome was total number of CPD during Week 12; - Secondary outcomes included number of CPD across weeks, toxin exposure, and severity of dependence and craving or withdrawal (17 dependent measures) | - Total number of CPD during Week 12 increased as the cumulative number of vulnerabilities increased (p = 0.004) but decreased as the level of nicotine content decreased (p<0.001); - There was no significant interaction between cumulative vulnerability and nicotine dose on CPD (p = 0.67); - Policies that reduce nicotine content in cigarettes to minimally addictive levels could benefit people in highly disparate groups who smoke, including those residing in rural areas or in other regions with overrepresentation of co-occurring vulnerabilities
Krebs et al. (2021) | - 33-week, two-arm, double-blind randomized trial; - Examined outcomes in response to the gradual tapering of nicotine among people who smoked over an extended period; - Participants were adults who smoked cigarettes daily (≥5 cigarettes per day), had less than a college degree, and had no plans to quit within the next 6 months; - Participants (n = 245) were randomized to two groups:; – RNC study cigarettes with nicotine content tapered every 3 weeks to final VLNC cigarettes (0.2 mg of nicotine per cigarette) for 6 weeks (n = 122); – UNC study cigarettes (11.6 mg of nicotine per cigarette) (n = 123); - Hershey, Pennsylvania, and Washington, DC | - Outcomes included acceptability of study cigarettes, as measured by attrition (primary outcome); compliance; reduction in cigarette dependence and tobacco biomarkers; and post-intervention cessation | - Attrition was higher in the RNC group (43%; n = 52) than it was in the UNC group (15%; n = 19) (adjusted hazard ratio = 3.4; 95% CI, 1.99–5.81); - At the end of the randomization period (ninth visit of the intervention), 174 participants remained in the study: 70 in the RNC group and 104 in the UNC group:; – Cotinine levels were 50% lower among participants in the RNC group (mean group difference = −137 ng/mL; 95% CI: −172 to −102) than they were among participants in the UNC group; – Participants in the RNC group smoked fewer cigarettes per day (−4.1; 95% CI: −6.44 to −1.75) and had lower levels of exhaled CO (−4.0 ppm; 95% CI: −7.7 to −0.4) than participants in the UNC group; – Among 62 participants in the RNC group who were assessed for biochemical compliance when smoking VLNC cigarettes, 47% (n = 29) were compliant, 34% (n = 21) were partially complaint, and 19% (n=12) were noncompliant; – At the ninth visit, 44% (n = 31) of participants in the RNC group chose to continue to receive VLNC cigarettes, 24% (n = 17) returned to smoking their own brands of cigarettes, and 31% (n=22) chose to make a quit attempt:; - Among those who chose a quit attempt, 27% (n = 6) were quit at the 3-month follow-up; - Participants in the RNC group were more likely to quit if they were determined to be compliant in the use of VLNC cigarettes; - Differential dropout and noncompliance with the study
Foulds et al. (2022) | - Randomized controlled parallel group trial; - Examined the potential effects of reducing the nicotine content in cigarettes to very low levels among people who smoked and had affective disorders; - Participants included adults who smoked, had a current (n = 118) or lifetime (n = 70) anxiety or unipolar mood disorder, and were not planning to quit smoking in the next 6 months; - After two baseline periods, 188 adults were randomized to two study groups:; – UNC research cigarettes (11.6 mg of nicotine per cigarette) (n = 94); – RNC research cigarettes (n = 94) where, during a five-step phase over 18 weeks, the nicotine content per cigarette was progressively reduced to 0.2 mg of nicotine per cigarette; - After randomization, 143 respondents (69 in the RNC group and 74 in the UNC group) entered the treatment choice phase where they were offered the choice of receiving assistance to quit smoking, continuing to receive free research cigarettes, or resuming smoking their own brands of cigarettes during a 12-week follow-up period; - Penn State University, Hershey, Pennsylvania; and Massachusetts General Hospital, Boston, Massachusetts | - The pre-registered primary outcome was plasma cotinine (metabolite of nicotine); - Study also measured group mean differences in:; – Other biomarkers of nicotine and toxicant exposure (exhaled CO, NNAL, GSSP:GSH ratio, 8-isoprostanes, and hydroxypyrene); – Smoking behavior (number of CPD); – Dependence measures (FTCD, PSCDI, HONC, MNWS, and QSU scales); – Severity of psychiatric symptoms (Kessler K6, OASIS, QIDS, PSS, and CES-D); – Health status indicators (blood pressure, heart rate, weight, waist:hip ratio, FEV1, and CCQ) | - Compared with participants in the UNC group at the last randomization phase visit, those in the RNC group had significantly lower:; – Plasma cotinine (difference between groups = −175.7 ng/ml; 95% CI, −218.3 to −133.1); – NNAL (difference between groups = −0.54; 95% CI, −1.02 to −0.06); – Exhaled CO (difference between groups = −7.86 ppm; 95% CI, −12.06 to −3.66); – Number of CPD (difference between groups = −4.543; 95% CI, −7.43 to −1.64); – Cigarette dependence, as measured by the FTCD, PSCDI, and HONC scores; - No between-group differences were found on a range of other biomarkers (e.g., 8-isoprostanes) or health indicators (e.g., blood pressure) or on five psychiatric questionnaires, including the Kessler K6 measure of psychological distress; - At the end of the subsequent 12-week treatment choice phase, those randomized to the RNC group were more likely to have quit smoking, based on initial intent-to-treat sample (n = 188; 18.1% RNC vs. 4.3% UNC; p = 0.004)
Higgins et al. (2022a) | - Secondary analysis of three 12-week randomized clinical trials examining research cigarettes with different levels of nicotine content (0.4, 2.4, and 15.8 mg/g) (Higgins et al. 2020); - Analysis examined whether the relative reinforcing effects of smoking increase with greater cumulative vulnerability and whether cumulative vulnerability moderates responses to reduced levels of nicotine content in cigarettes.; - Participants (n = 775) were categorized as having low (0–1), moderate (2–3), or high (4–7) cumulative vulnerability; - Vulnerabilities included rural residence, opioid use disorder, affective disorder, low level of educational attainment, poverty, unemployment, and physical disability | - A CPT was used to assess the relative reinforcing effects of participants’ usual brand of cigarettes at baseline and study cigarettes during the 12-week trial; - The CPT is a behavioral-economic task wherein participants estimate the likely demand for smoking over 24 hours under escalating cigarette price; - Demand is characterized by two factors: amplitude (demand volume at zero or minimal price) and persistence (demand sensitivity to price) | - Greater cumulative vulnerability was associated with greater demand amplitude (p <0.0001) and persistence (p = 0.0003) for usual-brand cigarettes; - Demand amplitude for study cigarettes increased with increasing cumulative vulnerability (p <0.001) and decreased with decreasing levels of nicotine content (p <0.001); - There was evidence of moderation on demand persistence in which larger reductions at the 0.4 mg/g compared with 15.8 mg/g doses were observed among participants with low compared to moderate or high cumulative vulnerability (p = 0.04); the relative reinforcing effects of smoking clearly increased with greater cumulative vulnerability; - Reducing levels of nicotine content could reduce demand amplitude across cumulative vulnerability levels but reductions in demand persistence may be more limited among those with greater cumulative vulnerability
Lin et al. (2022) | - Two parallel randomized controlled trials; - Examined the gradual reduction of nicotine content in cigarettes (from 11.6 to 0.2 mg of nicotine per cigarette in the VLNC condition) versus 11.6 mg of nicotine per cigarette in the UNC condition) over an 18-week period among people who smoked cigarettes and had low socioeconomic status and mental health conditions; - Investigated the treatment effects of gradually reducing levels of nicotine from commercial to VLNC research cigarettes on reducing smoking exposure between people who smoke menthol and nonmenthol cigarettes; - United States | - Number of CPD, cotinine, and expired CO; - Adherence to VLNC research cigarettes; compared the odds of being adherent with using only VLNC research cigarettes by menthol preference of participants | - Compared with UNC cigarettes, VLNC cigarettes were associated with significant reductions in cotinine, number of CPD, expired CO levels, nicotine dependence, and symptomology; - The pooled OR of being adherent with using only VLNC study cigarettes in the gradual nicotine reduction arm for people who smoked nonmenthol versus menthol cigarettes was 2.6 (95 % CI,1.0–6.4; p = 0.04); - When nicotine is lowered to non-addictive levels, results indicate an independent effect of menthol on the need to sustain nicotine intake in people who smoke cigarettes
Morgan et al. (2022) | - Secondary analysis of three 12-week randomized clinical trials examining research cigarettes with different levels of nicotine content (0.4, 2.4, and 15.8 mg/g) (Higgins et al. 2020); - Focused exclusively on adherence among adults from disparate populations who were assigned to use VLNC cigarettes (0.4 mg/g) (n = 286):; – Women of reproductive age who were socioeconomically disadvantaged (n = 93); – Adults with opioid use disorder who were enrolled in opioid-assisted treatment (n = 92); – Adults with affective disorders (n = 101); - Goal was to identify characteristics of people who would require additional assistance if a nicotine reduction policy were implemented | - Logistic and linear regressions modeled predictors of two measures of adherence at the Week-6 and Week-12 assessments: (1) changes in cotinine relative to baseline); and (2) full adherence (yes/no), considered as a 90% reduction in cotinine relative to baseline; - Predictors included satisfaction with study cigarettes, craving, severity of nicotine dependence, withdrawal, population group, baseline symptoms of affective disorders, and sociodemographic characteristics | - Severity of nicotine dependence was negatively associated with both adherence measures at Week 6 (p <0.01); - Increased satisfaction with study cigarettes and age were positively associated with both adherence measures at Weeks 6 and 12 (p <0.01); - Adults receiving opioid maintenance treatment exhibited reduced adherence and were less likely to reach full adherence at Week 12 compared with women who were socioeconomically disadvantaged (p = 0.02)
Reed et al. (2022) | - Secondary analysis of a 6-week randomized controlled trial examining the effects of VLNC cigarettes in adults with serious mental illness from November 2014 to November 2017 (Tidey et al. 2019); - Examined the prevalence and predictors of non-adherence among trial participants with serious mental illness; - Adults with serious mental illness who smoked daily and were not trying to quit (n = 58) were randomized to receive VLNC cigarettes (0.4 mg/g; n = 30) or NNC cigarettes (15.8 mg/g; n = 28); - Providence, Rhode Island | - Assessed predictors of biologically assessed non-adherence in participants assigned to the VLNC group; - Predictors included subjective responses to questions about VLNC cigarettes measured by the CES (subscales: satisfaction, psychological reward, enjoyment of respiratory tract sensations, craving reductions, and aversion), baseline nicotine dependence and dependence motives, and severity of psychiatric symptoms; - Series of linear models regressing non-adherence metrics onto covariates (gender and menthol preference) and focal predictors | - Nearly all participants (96%) were estimated to be less-than-completely adherent to VLNC cigarettes; - Lower enjoyment ratings of respiratory tract sensations of VLNC cigarettes predicted a greater degree of non-adherence (beta = −0.40; 95% CI, −0.71 to −0.10; standard error = 0.14)

Notes: AIMS = Abnormal Involuntary Movements Scale; BARS = Barnes Akathisia Rating Scale; BPRS = Brief Psychiatric Rating Scale; CCQ = Clinical COPD Questionnaire; CEMA = N-Acetyl-S-(2-cyanoethyl)-L-cysteine (a urinary metabolite of acrylonitrile); CES = Cigarette Evaluation Scale; CES-D = Center for Epidemiological Studies-Depression Scale; CI = confidence interval; CO = carbon monoxide; CPD = cigarettes smoked per day; CPT = cigarette purchase task; FEV1 = forced expiratory volume in 1 second; FTCD = Fagerstrom Test of Cigarette Dependence; FTND = Fagerstrom Test of Nicotine Dependence; g = gram; GSSP:GSH = ratio of glutathione to oxidized glutathione; HONC = Hooked on Nicotine Checklist; LNC = low-nicotine-content; mg = milligram; mL = milliliter MNWS = Minnesota Nicotine Withdrawal Scale; NDSS = Nicotine Dependence Syndrome Scale; ng = nanogram; nmol = nanomole; NNAL = 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanol; NNC = normal-nicotine-content; OASIS = Overall Anxiety Severity and Impairment Scale; OR = odds ratio; PANAS = Positive and Negative Affective Schedule; PANSS = Positive and Negative Syndrome Scale; PheT = phenanthrene tetraol; ppm = parts per million; PSCDI = Penn State Cigarette Dependence Index; PSS = Perceived Stress Scale; QIDS = Quick Inventory of Depressive Symptomatology; QSU = Questionnaire on Smoking Urges-short form; RNC = reduced-nicotine-content; SANS = Scale for Assessment of Negative Symptoms; SEM = standard error of the mean; TNE = total nicotine equivalents; UNC = usual-nicotine-content; VLNC = very-low-nicotine-content; WISDM = Wisconsin Inventory of Smoking Dependence Motives.

A scoping review identified and synthesized 18 original research studies published between January 2000 and October 20, 2021, about a very-low-nicotine-content cigarette product standard related to various population groups experiencing tobacco-related disparities, including people experiencing mental illness, substance use disorders, unemployment, or with low incomes; and people who identify as LGBTQI+ (Puljevic et al. 2023). The authors found that a very-low-nicotine-content cigarette product standard would likely be accepted by people from the population groups included in the review and would likely reduce smoking among those population groups, especially if supported by cessation treatment, such as nicotine replacement therapy (NRT). The authors noted that these findings are consistent with their previous review of 26 evidence syntheses, wherein they concluded that a very-low-nicotine-content cigarette product standard would likely notably reduce cigarette smoking among people experiencing mental illness, people experiencing socioeconomic disadvantage, pregnant women, women of childbearing age, and First Nations people (Puljevic et al. 2022, 2023). The authors cautioned that, although the studies in the scoping review showed that use of very-low-nicotine-content cigarettes reduced smoking, cigarette cravings, nicotine withdrawal, and nicotine dependence among the population groups studied, none of the studies examined the effectiveness of such a standard in promoting smoking cessation beyond 12 weeks (Puljevic et al. 2023). Additionally, the majority of the studies focused on people experiencing mental illness or substance use disorders, and the authors noted that only one of the studies reviewed included people who identify as LGBTQI+ (Denlinger-Apte et al. 2021) or people who experienced unemployment (Higgins et al. 2021). Furthermore, none of the studies reviewed included people living with HIV or experiencing homelessness or incarceration, although these populations were expressly included in the literature search (e.g., Puljevic et al. 2023).

A narrative review of studies conducted between 2010 and 2021 identified few studies investigating the effects of very-low-nicotine-content cigarettes in minoritized racial and ethnic groups, people who are socioeconomically disadvantaged, people who smoke menthol cigarettes, and pregnant women; no studies were found that investigated these effects among minoritized sexual orientation and gender identity groups, veteran or military populations, or people in underserved rural environments (Tidey et al. 2022). Additionally, few of the studies in the narrative review investigated the impact of these products on quit attempts because smoking cessation has not been a goal of most clinical trials to date. However, the authors noted that increases in abstinence were observed in studies focused on “vulnerable participants” and in studies that were not focused on “vulnerable populations” (Tidey et al. 2022).

The few studies that have examined the impact of reduced-nicotine-content cigarettes on smoking cessation are nonetheless promising. A randomized controlled parallel group trial found that, compared with usual-nicotine-content cigarettes, reduced-nicotine-content cigarettes increased smoking cessation among people with mood and/or anxiety disorders who were not planning to quit in the next 6 months, without worsening mental health (Foulds et al. 2022). Specifically, participants were randomly assigned to usual or reduced-nicotine-content cigarettes where the nicotine content was reduced over 18 weeks, then were offered the choice to either receive assistance to quit smoking, free research cigarettes, or to resume using their own cigarette brand during a 12-week follow-up period. After the 12-week treatment choice phase, those randomized to the reduced-nicotine-content cigarette group were significantly more likely to have quit smoking.

A similar double-blind randomized controlled trial examining the impact of reduced nicotine content on smoking-related outcomes among adults 18–65 years of age with lower SES found that reduced-nicotine-content cigarettes were associated with higher rates of quit attempts and successful quitting at 1 month and 3 months post-intervention compared with usual-nicotine-content cigarettes (Krebs et al. 2021). At 1 month post-intervention, the quit rate among participants in the reduced-nicotine-content cigarette group who chose to quit was 36% compared with 18% in the control group, and at 3 months, the quit rate was 27% and 18%, respectively.

Separately, in a trial of 775 men and women 18–70 years of age with affective disorders or opioid dependence and women 18–44 years of age with 12 or fewer years of education, those assigned to very-low-nicotine-content (0.4 mg/g) or low-nicotine-content (2.4 mg/g) cigarettes had lower dependence and reported more abstinent days and quit attempts compared to those assigned to regular cigarettes (15.8 mg/g); few differences were observed between the very-low-nicotine-content and low-nicotine-content groups (Higgins et al. 2020). The extent to which the use of reduced-nicotine-content cigarettes leads to cessation among population groups experiencing tobacco-related disparities that were not included in these studies is not known (Puljevic et al. 2022).

Compared with complete cessation, reduced cigarette consumption alone still results in elevated health risks (USDHHS 2020). Furthermore, a secondary analysis of an RCT found that, although reduced-nicotine-content cigarettes led to reductions in the number of cigarettes smoked per day and reduced exposure to nicotine regardless of race, education, and gender, the magnitude of effect on nicotine exposure (measured by total nicotine equivalents) was lower for Black versus White adults (Carroll et al. 2021). This could be due to the continued availability of high-nicotine-content cigarettes during the trial, which would not be the case if a product standard were implemented for all cigarettes. It also could be due to differences by race and ethnicity in exposure to carcinogens like 4-(methylnitrosamino)-1-(3)pyridyl-1-butanol (NNAL) among people who smoke at the same frequency, especially among people who smoke at lower frequencies (Benowitz et al. 2011; Murphy et al. 2018). For example, a review of analyses of the Multiethnic Cohort Study found that African American people had significantly higher levels of NNAL than White people, and Japanese American people had the lowest levels (Murphy et al. 2018). Such differences in exposure could be due in part to differences in smoking behaviors, including the type of cigarette smoked (e.g., menthol vs. nonmenthol) and the depth of inhalation (Benowitz et al. 2011). Because Black people who reduce their cigarette consumption may not reduce their risk of exposure to carcinogens as much as people of other races who similarly reduce their consumption, they may be one population group for which additional support is warranted to achieve successful smoking cessation. Other studies have concluded that because people from other population groups (e.g., adults receiving opioid maintenance treatment or people with serious mental illness) experiencing tobacco-related disparities had difficulty adhering to very-low-nicotine-content cigarettes when normal-nicotine-content cigarettes were available, they may also benefit from additional cessation support when implementing a reduced-nicotine-content product standard (Morgan et al. 2022; Reed et al. 2022).

Many people who experience tobacco-related disparities smoke menthol cigarettes (see Chapter 2, Table 2.6). People who smoke menthol cigarettes may be less responsive to a reduced-nicotine-content product standard if menthol-flavored reduced-nicotine-content cigarettes are available (Donny and White 2022; Lin et al. 2022; Tidey et al. 2022). For example, RCT participants who were randomized to the very-low-nicotine-content cigarette arm and who received menthol cigarettes (based on their usual flavor preference) for 20 weeks had (a) smaller reductions in smoking and toxicant exposure than those randomized to receive very-low-nicotine-content nonmenthol (based on usual flavor preference) cigarettes and (b) did not have increased odds of abstinence at the end of the trial unlike the very-low-nicotine-content nonmenthol cigarette recipients (Denlinger-Apte et al. 2019).

In addition, Lin and colleagues (2022) conducted two parallel RCTs of gradually reduced levels of nicotine content in cigarettes versus usual-nicotine-content cigarettes over 18 weeks in (1) people with lower SES who smoke cigarettes and (2) people with mental health conditions who smoke. Participants were assigned to menthol-flavored study cigarettes based on their usual flavor preference. Very-low-nicotine-content cigarettes were associated with reductions in cotinine, cigarettes smoked per day, expired carbon monoxide levels, and nicotine dependence symptoms. Associations did not differ between menthol and nonmenthol cigarettes. However, in the trial involving people with lower SES, people who smoked very-low-nicotine-content menthol cigarettes had a lower cotinine reduction than those who smoked very-low-nicotine-content nonmenthol cigarettes. Additionally, the pooled odds ratio of being adherent with using only very-low-nicotine-content study cigarettes for people who smoked nonmenthol versus menthol cigarettes was 2.6 (95% confidence interval [CI], 1.0–6.4), indicating higher adherence to very-low-nicotine-content study cigarettes for people who smoked non-menthol cigarettes. The authors concluded that there was “an independent effect of menthol on the need to sustain nicotine intake” among people with nicotine dependence who smoke menthol cigarettes (Lin et al. 2022, p. 131).

As discussed later in this chapter, in April 2022, FDA announced a proposed product standard prohibiting menthol as a characterizing flavor in cigarettes (FDA 2022a). A policy to reduce nicotine content in cigarettes to minimally addictive or nonaddictive levels is expected to have a strong effect on preventing smoking initiation and reducing cigarette consumption among people who currently smoke, including among many population groups experiencing tobacco-related disparities. It is expected that this policy could be even more impactful if adopted and implemented in concert with complementary efforts such as restrictions on flavored tobacco products, particularly menthol products (see Chapter 8).

Education campaigns may help to maximize the public health benefit of a policy that reduces nicotine content in cigarettes to minimally addictive or nonaddictive levels by providing consumers with information about the policy and its rationale, as well as cessation resources, prior to or during implementation (Benowitz et al. 2015; Popova et al. 2019; Villanti et al. 2019a). Education campaigns could also help address misperceptions that reduced-nicotine-content cigarettes are less harmful (Denlinger-Apte et al. 2017). This may be particularly important with respect to the efficacy of this type of policy among members of minoritized racial and ethnic groups who smoke (Villanti et al. 2019a). Studies have shown that some people who smoke misperceive lower-nicotine cigarettes as less harmful than higher-nicotine cigarettes, and that this misperception is more common among Black and other non-White people who smoke as compared with White people who smoke (Denlinger-Apte et al. 2017; Byron et al. 2018; Mercincavage et al. 2019; Villanti et al. 2019a).

There is public support for federal policies to reduce nicotine levels in cigarettes in the United States and in other countries (Fix et al. 2011; Connolly et al. 2012; Pearson et al. 2013; Ali et al. 2019; Smith et al. 2021b). Although some variability exists with respect to which population groups most strongly support this type of policy, possibly owing to study design, four studies show that overall support throughout the United States has ranged from 48% (Pearson et al. 2013) to 81% (Ali et al. 2019). Three of these four studies assessed support by demographic characteristics. The studies indicated greater support among non-Hispanic African American people (Pearson et al. 2013) and Hispanic people (Connolly et al. 2012) than among White people (Ali et al. 2019). Two of the studies found similar levels of support regardless of smoking status (Pearson et al. 2013; Ali et al. 2019).

In summary, reducing the level of nicotine in cigarettes to make them minimally addictive or nonaddictive is expected to prevent and reduce tobacco use, resulting in substantial reductions in tobacco-related death and disease and in healthcare expenditures (USDHHS 2014; Federal Register 2018). The evidence discussed earlier suggests that this policy would reduce cigarette consumption among many population groups experiencing tobacco-related disparities and that there is support for this policy among non-Hispanic Black people and Hispanic people regardless of smoking status. Evaluation of any reduced-nicotine product standard will be important to monitor progress on reducing tobacco product use and health disparities.

#### New Tobacco Products

As discussed earlier, under the Tobacco Control Act, FDA’s decisions to authorize new tobacco products to enter the U.S. market require an assessment of whether the manufacturer’s application demonstrates that doing so would be appropriate for the protection of public health, considering the risks and benefits to the population as a whole and taking into account the likely impact on initiation and cessation (Family Smoking Prevention and Tobacco Control Act 2009, 21 U.S.C. § 387j(c)(4)).

There are numerous complex and interactive factors that, regardless of the potential for reduced toxicity, may influence whether the presence of new products in the tobacco market increases or decreases overall harm (USDHHS 2016, 2020), including among people who experience tobacco-related health disparities. Most studies to date have focused on the potential impact on the general population, rather than the potential relationship to health disparities. Beyond research related to the products themselves, research is also needed to understand how modified risk claims (i.e., claims of reduced harm or reduced exposure to harmful chemicals) affect initiation, use, and cessation (McKelvey et al. 2020; Ahuja et al. 2021; Berg et al. 2021a, b) among people experiencing disparities.

Countries have taken a range of regulatory approaches regarding newer products such as e-cigarettes (Kennedy et al. 2017; WHO 2021) and heated tobacco products (Campaign for Tobacco-Free Kids 2020; WHO Study Group on Tobacco Product Regulation 2021). FDA has authorized the marketing of certain e-cigarettes and heated tobacco products in the United States, and these products are subject to the same FDA regulations that apply to all tobacco products, such as the prohibition on their sale to people under 21 years of age (FDA n.d.b). Many states, territories, tribes, and local governments have updated their tobacco control laws so that they explicitly apply to these products, although approaches vary (Public Health Law Center 2018b, 2022b). For example, some states have included these products in their statutes that impose a tax on cigars or smokeless tobacco products, and other states have set up a separate taxing structure (e.g., a specific tax on the amount of consumable liquid used in e-cigarettes) (Chaloupka and Tauras 2020). There is a lack of evaluation data concerning the impact of these policies for newer tobacco products on tobacco-related disparities specifically.

Population groups that are likely to experience tobacco-related disparities with respect to combustible or smokeless tobacco may also experience disparities in exposure to marketing for and use of new products as well as in dual use of new products and cigarettes (see Chapters 2 and 5). However, there is little information about the regulatory approaches for e-cigarettes, heated tobacco products, and other new products that could reduce—or inadvertently exacerbate—tobacco-related health disparities.

Dual use of e-cigarettes and combusted tobacco products is a public health concern that presents important considerations for regulators. On the basis of data from the 2017, 2018, and 2020 Behavioral Risk Factor Surveillance Survey, e-cigarette use increased more for some groups of adults than for others. For example, e-cigarette use increased more among (1) adults who formerly smoked cigarettes than among adults who never or currently smoke cigarettes; (2) adults who use smokeless tobacco than those who do not use it; (3) adults who used other substances (including cannabis and alcohol) than those who do not use these substances; and (4) adults who have depression than adults without depression (Boakye et al. 2022). While some people might be using e-cigarettes in an attempt to transition away from combustible tobacco product use, the increase in adult e-cigarette use may also be related to multiproduct use (Chen-Sankey and Bover-Manderski 2022). According to data from the 2021 National Health Interview Survey (NHIS), 4.5% of U.S. adults currently used e-cigarettes (Cornelius et al. 2023a), of whom 30.3% had never smoked cigarettes and 29.4% currently used cigarettes, also known as dual use (CDC 2023). E-cigarette use among those who had never smoked was more common among younger versus older adults, while dual use was more common among older versus younger adults. Dual use of electronic and combustible tobacco products may result in worse respiratory symptoms and greater exposure to toxicants than cigarette smoking alone or e-cigarette use alone (Goniewicz et al. 2018; Reddy et al. 2021). Continued monitoring of the impact of e-cigarettes and dual use on tobacco-related disparities is warranted.

Data from the Population Assessment of Tobacco and Health (PATH) Study found that shifting from smoking cigarettes exclusively to using e-cigarettes exclusively between 2013–2014 and 2014–2015 was less likely among non-Hispanic Black and Hispanic people (compared with non-Hispanic White people) and less likely among people of lower SES (compared with those of higher SES) (Harlow et al. 2019). The study also found that Black people, Hispanic people, and people of lower SES were more likely to hold the unsubstantiated belief that e-cigarettes are more harmful than cigarettes. Two studies based on data from the PATH Study, the NHIS, and the Tobacco Use Supplement to the Current Population Survey (TUS-CPS) that were collected between 2014 and 2016 showed a greater likelihood of dual use of e-cigarettes and cigarettes among people with lower educational attainment (compared to those who have completed one or more years of college) and lower incomes (compared to those with household incomes greater than 200% of the federal poverty level). The evidence was mixed regarding dual use among people of different races and ethnicities (Friedman and Horn 2019; Hirschtick et al. 2021).

Several studies mentioned here present data that were collected before the rise in prevalence of pod- or cartridge-based e-cigarettes and similar-looking disposable e-cigarettes. More research is needed to better understand the regulatory approaches for e-cigarettes, heated tobacco products, and new tobacco products that may enter the market with the potential to reduce or inadvertently exacerbate tobacco-related health disparities in smoking initiation, quitting, and disease outcomes.

The evidence base continues to grow about newer products and their relationship to disparities in tobacco use and health outcomes. In the meantime, given the known harms of combusted tobacco products (USDHHS 2014), the known disparities in their use (USDHHS 1998; Park-Lee et al. 2022; Cornelius et al. 2023b) (see Chapter 2), the known harms of dual use of combusted tobacco products and e-cigarettes (Goniewicz et al. 2018; Owusu et al. 2019; Reddy et al. 2021; Smith et al. 2021a), and the known benefits of utilization of evidence-based cessation treatments (USDHHS 2020), it is important to prioritize regulatory efforts that eliminate the use of combusted tobacco products at the population level. Simultaneous efforts are warranted to advance access to and use of evidence-based tobacco cessation treatment, particularly for people experiencing health disparities.

#### Elimination of Flavors in Tobacco Products

The Tobacco Control Act prohibited cigarettes with characterizing flavors other than tobacco or menthol. (See Chapter 3 of the current report for a summary of the science of flavors in tobacco products and how inclusion of flavors may contribute to tobacco-related health disparities). As discussed earlier in this chapter, FDA has the authority to establish product standards, including those that prohibit characterizing flavors or flavor additives in tobacco products, such as menthol in cigarettes. Territorial, tribal, state, and local sales restrictions on flavored products are discussed later in this chapter. In May 2022, FDA announced two proposed tobacco product standards: one proposed rule prohibiting menthol as a characterizing flavor in cigarettes and another proposed rule prohibiting all characterizing flavors (other than tobacco) in cigars (FDA 2022a).

In addition, manufacturers must obtain FDA authorization to market new tobacco products, including e-cigarettes, and FDA makes determinations based on the public health standard discussed previously. This requirement also applies to flavored e-cigarettes and flavored e-cigarette liquids. Because of their popularity among youth, FDA announced, in February 2020, intent to prioritize its enforcement activities to remove from the market any flavored, cartridge-based, e-cigarette product (other than tobacco- or menthol-flavored products) unless and until FDA authorized that product for sale (FDA 2020). All new tobacco products on the market without FDA authorization are being illegally marketed. Therefore, FDA can, and has, pursued enforcement action at any time against illegally marketed products (FDA 2020, 2023). As of April 2023, the only e-cigarette products that have received marketing authorization from FDA have been tobacco flavored (FDA n.d.b). Thus, although some flavored e-cigarettes remain on the market, it is not yet known whether FDA will determine that it is appropriate for the protection of public health for any flavored e-cigarettes to be on the market.

Since 2014, e-cigarettes are the tobacco product youth most commonly use (Cooper et al. 2022). There are disparities in use among different youth population groups (Park-Lee et al. 2022). For example, in 2022, a higher prevalence of e-cigarette use was observed among White high school students (16.9%; 95% CI, 14.6–19.5) than among Black (11.1%; 95% CI, 8.3–14.7), Hispanic (12.2%; 95% CI, 10.7–14.0), American Indian or Alaska Native (14.6%; 95% CI, 9.4–22.0) and Multiracial (14.3%; 95% CI, 11.0–18.3) high school students; however, confidence intervals overlapped for some population groups, so these differences may not be statistically significant (Park-Lee et al. 2022). Eighty-five percent of youth who currently use e-cigarettes report using flavored products (Cooper et al. 2022).

Nearly all people who smoke begin smoking before 25 years of age (USDHHS 2012). If someone does not use tobacco products regularly by 25 years of age, it is highly unlikely that they will start (USDHHS 2012). Previous Surgeon General’s reports and Chapter 3 of this report document that flavored tobacco products mask the harshness of tobacco; flavors are particularly appealing to young people and promote initiation and sustain tobacco use among young people; menthol enhances the effects of nicotine on the brain and can make products more addictive; and menthol reduces the likelihood of cessation, particularly among Black people (Tobacco Products Scientific Advisory Committee 2011; USDHHS 2012, 2014, 2020; Brody et al. 2013; Palmatier et al. 2013; IOM 2015; Audrain-McGovern et al. 2016, 2019; WHO 2016b; Henderson et al. 2017; Villanti et al. 2019b, 2021; Weinberger et al. 2019; Rose et al. 2020b; Brouwer et al. 2022; FDA 2022c). In addition to menthol, factors contributing to the reduced likelihood of cessation among Black people could include less access to cessation treatments, as well as social determinants that may make it harder to quit (Nollen et al. 2019).

Despite overall decreases in smoking prevalence and menthol smoking prevalence, the proportion of people who smoke who use menthol cigarettes has increased, particularly among population groups that experience tobacco-related disparities (Seaman et al. 2022). Given both the existence of disparities in tobacco product use and the evidence related to the role of menthol and other flavors with respect to tobacco use initiation and progression to regular use, flavors play a key role in tobacco product use.

Because flavored tobacco products are commonly used by young people and certain population groups—who also initiate tobacco use primarily as youth or young adults—eliminating flavors in tobacco products is expected to lead to a reduction in tobacco product use and tobacco-related health disparities (FDA 2013; Villanti et al. 2016; Huang et al. 2017a; Kowitt et al. 2017; Zare et al. 2018; Goldenson et al. 2019; Chen-Sankey et al. 2021). Studies show that policies that prohibit the sale of flavored tobacco products reduce tobacco use. For example, the Tobacco Control Act’s prohibition on cigarettes with characterizing flavors other than menthol or tobacco was associated with a 17% reduction in the prevalence of cigarette smoking among youth and a 58% decrease in number of cigarettes smoked by youth (Courtemanche et al. 2017). Additionally, in a modeling study of the Tobacco Control Act’s flavor prohibition, Rossheim and colleagues (2020) reported a reduction in the predicted probability of cigarette smoking among youth and young adults in 2017 compared to the model-predicted probability of cigarette smoking in the absence of the flavor prohibition. However, the Tobacco Control Act’s effect on youth tobacco use likely was diminished by the continued availability of menthol cigarettes and other flavored noncigarette tobacco products, such as little cigars and cigarillos (Courtemanche et al. 2017; Rossheim et al. 2020).

Evaluations have shown that state and local restrictions on the sale of flavored products reduced the sale of such products, as well as the sale of unflavored products in some cases; reduced the odds of youth trying flavored tobacco products and the odds of youth ever using tobacco products; and reduced current use of tobacco products among youth (Farley and Johns 2017; Rogers et al. 2017, 2020; Kingsley et al. 2019, 2022; Pearlman et al. 2019; Gammon et al. 2021; Asare et al. 2022; Satchell et al. 2022; FDA 2022c). In two Minnesota communities, flavor policies were associated with decreases in the sales of each tobacco product category, including cigarettes, cigars, smokeless tobacco, and e-cigarettes, as well as smaller increases in the prevalence of youth tobacco use from 2014 to 2019 as compared with the rest of the state (Olson et al. 2022a,b). Four of the policies that were evaluated by these state and local evaluation studies prohibited the sale of menthol cigarettes in addition to other flavored tobacco products (Yang et al. 2020; Gammon et al. 2021; Asare et al. 2022; Kingsley et al. 2022; Olson et al. 2022a,b; Satchell et al. 2022). These and other studies are described in Table 7.3.

Similarly, a 2009 prohibition on flavor additives—except menthol—in cigarettes, little cigars, and cigarillos in two Canadian provinces reduced unit sales of cigars and flavored cigars (Chaiton et al. 2019). A 2010 policy in Canada prohibiting the sale of flavored cigarillos (including menthol) throughout Canada and requiring any unflavored cigarillos to be sold in packs of 20 reduced current use of cigarillos among youth and young adults and resulted in a net decrease in all cigar smoking (Nguyen and Grootendorst 2015). Other studies in Canada have shown decreases in menthol cigarette sales and total cigarette sales following the removal of menthol cigarettes from the market, a greater proportion of people who smoked menthol cigarettes making a quit attempt compared with people who smoked nonmenthol cigarettes, and a significantly higher rate of reported smoking cessation 2 years later for people who smoked menthol cigarettes compared with people who smoked nonmenthol cigarettes (Chaiton et al. 2018, 2020b,c, 2021a,b, 2022; Chung-Hall et al. 2022; FDA 2022c).

Table 7.3 Studies of the impact of prohibiting the sale of flavored tobacco products on tobacco product use

Study | Design, population, and location | Primary outcome(s) | Results
Hymowitz et al. (1995) | - Cross-sectional survey (baseline menthol questionnaire).; - Administered to a total of 473 African American and White adults who participants in a stop smoking study. | - Compared use of menthol cigarettes and reasons for smoking menthol cigarettes | - Although White people in the study smoked more cigarettes per day than African American people in the study, a significantly greater proportion of African American males (79%) and females (79%) smoked menthol cigarettes than White males (13%) and females (20%) (p <0.01); - More than half (56%) of African American people and more than one-quarter (28%) of White people reported they would not smoke nonmenthol cigarettes if they could not smoke menthol cigarettes (p <0.01); - African American people (83%) were more likely than White people (74%) to report that menthol cigarettes have a better taste than nonmenthol cigarettes; - African American people (48%) were more likely than White people (21%) to cite that menthol cigarettes were easier to inhale compared with nonmenthol cigarettes
Nguyen and Grootendorst (2015) | - Pre-post design; - Used data from 2007–2011 Canadian Tobacco Use Monitoring Surveys (n = 46,080) to assess outcomes of the Canadian government’s policy that in July 2010 banned the sale of flavored cigarillos and required unflavored cigarillos to be sold in packs of at least 20 units; - Constructed a segmented regression model to track trends in outcome variables | - Assessed changes in the use of cigarillos and regular cigars (potential substitutes) after the policy was implemented | - Youth and young adults, 15–24 years of age:; – For cigarillos, the prevalence of past-30-day use declined significantly after the policy was implemented, from 13.7% to 9.3% (p <0.000) among male respondents and from 5.3% to 3.3% (p = 0.001) among female respondents; in regression analysis, past-30-day use declined 22% (2.3 percentage points); – For regular cigars, the prevalence of past-30-day use declined insignificantly among male respondents, from 5.8% to 4.9% (p = 0.206), and increased insignificantly among female respondents, from 0.8% to 0.9% (p = 0.673); - Adults, 25–65 years of age:; – Changes in the prevalence of past-30-day use of cigarillos and regular cigars were small and statistically insignificant after the policy was implemented
Courtemanche et al. (2017) | - Pre-post, cross-sectional design; - Secondary analysis of data from the National Youth Tobacco Survey (1999, 2000, 2002, 2004, 2006, 2009, 2011, 2012, and 2013 cross-sectional surveys); – Pooled n = 197,834 youth, 11–19 years of age; – School-based, nationally representative sample of middle school and high school students; – In 2013, 74.8% of sampled schools and 90.7% of eligible students within schools participated; - Assessed the association between FDA’s ban on flavored cigarettes (excluding menthol) in 2009 and various tobacco use behaviors among adolescents; - Regression analysis controlled for covariates: age, gender, race and ethnicity, and national level tax-inclusive prices of cigarettes and other tobacco products | - Past-30-day use of cigarettes, cigars, smokeless tobacco, pipe tobacco, tobacco products excluding cigarettes, and any tobacco product; - Cigarettes smoked during the past 30 days (among youth who smoked cigarettes); - Menthol cigarette use (among youth who smoked cigarettes); - Econometric strategy to estimate the covariate-adjusted deviation from the outcome’s trend after 2009 | - In adjusted analyses, the flavor prohibition was significantly associated with:; – 17.1% reduction in the likelihood of cigarette smoking; – 59% fewer cigarettes smoked per month among youth who smoked cigarettes; – 45% increase in the probability that a person who smoked used menthol cigarettes; – 34.4% increase in the prevalence of cigar use; – 54.6% increase in the prevalence of pipe use; – 14.2% increase in the use of non-cigarette tobacco products; - By race and ethnicity, the odds of smoking cigarettes after the flavored cigarette ban was implemented were lower among Black (OR = 0.558) and Asian (OR = 0.372) adolescents than among White adolescents (p <0.001); - The odds of smoking cigarettes after the flavored cigarette ban was implemented were higher among American Indian (OR = 1.419) adolescents compared to White adolescents; - Compared with White adolescents who smoked cigarettes, the use of menthol cigarettes increased significantly among adolescents in all racial and ethnic groups, except among American Indian adolescents who smoked cigarettes, for which no association was observed; - Results suggest that after a ban on flavored cigarettes, adolescents who smoke may substitute with menthol cigarettes or other tobacco products that may be flavored
Farley and Johns (2017) | - Pre-post, cross-sectional design with one post-policy time point; - Compared 2010 and 2013 data for New York City from the Youth Risk Behavior Survey:; – 2010: n = 1,708 students from 28 schools; – 2013: n = 8,814 students from 81 schools; - Analyzed data on retail tobacco sales of cigars and smokeless and other tobacco products before and after a ban in October 2009 on sales of all flavored tobacco products (excluding menthol cigarettes) in New York City; - Multivariable logistic regression analysis adjusted for sex, race and ethnicity, age, and current or ever use of selected tobacco products | - Assessed changes in overall inflation-adjusted sales of flavored and non-flavored tobacco products, by product type; - Multivariable logistic regression estimated changes in (a) ever use of flavored tobacco products and of any tobacco product and (b) the prevalence of smoking among adolescents | - Sales of flavored tobacco products declined by 87% overall (p <0.001) after enforcement of the ban; - In adjusted models and compared with adolescents in 2010, adolescents in 2013 had:; – 37% lower odds of ever trying flavored tobacco products (aOR = 0.63; 95% CI, 0.52–0.77); – 28% lower odds of using any type of tobacco product (aOR = 0.72; 95% CI, 0.62–0.85); – Non-significant change in current smoking prevalence (p = 0.114); - Male students were less likely than female students to have ever tried flavored tobacco products (aOR = 0.79; 95% CI, 0.64–0.98); - Black students (aOR = 0.46; 95% CI, 0.35–0.61) and Asian students (aOR = 0.47; 95% CI, 0.34–0.66) were less likely than White students to use any type of tobacco product; - Black students (aOR = 0.36; 95% CI, 0.21–0.62) were less likely to currently smoke than White students
Chaiton et al. (2018) | - Pre-post, repeated longitudinal design with no control or comparison; - Evaluated associations of a full ban on menthol cigarettes—implemented in January 2017 in Ontario, Canada—on smoking behaviors of people, 16 years of age or older; - Conducted phone surveys from September to December 2016 using random-digit dialing to call residents, 16 years of age or older, of Ontario who had smoked at least one menthol cigarette in the past year and smoked in the past month (n = 325); - Contacted participants through an online survey for follow-up in February 2017 (1 month after implementation of the ban) (n = 206) | - Compared respondents’ planned behaviors before the ban on menthol cigarettes with their actual behaviors 1 month after the ban | - Most people (n = 123; 59.7%) who smoked menthol cigarettes indicated before the policy that they would switch to or use only nonmenthol cigarettes, but only 51 people (28.2%) had done so at follow-up; - Before the policy, 12 people (5.8%) reported that they would use other flavored tobacco or e-cigarette products (including menthol); at the 1-month follow-up, 60 people (29.1%) reported doing so; - Thirty people (14.5%) indicated before the policy that they would attempt to quit smoking; at the 1-month follow-up, 60 people (29.1%) reported doing so; - Among people who made a quit attempt, 16 (80.0%; 95% CI, 56.3%–92.5%) of those who primarily smoked menthol cigarettes at baseline reported that the policy affected their decision to quit at least a little compared with 10 (25.6%; 95% CI, 14.1%–41.0%) of those who smoked menthol cigarettes only occasionally
Kingsley et al. (2019) | - Post-design with matched control community; - Cross-sectional, difference-in-differences models, with post-policy baseline (October 2016) and 6-month follow-up; - Conducted surveys from the Massachusetts Tobacco Control Program with students in Grades 9–12; - Retailer inventories in a census of all retailers in Lowell and Malden, Massachusetts; - Evaluated the short-term impact of a policy that restricted the sale of flavored tobacco products (not including menthol cigarettes) in a community (Lowell, Massachusetts) that enforced the restriction policy (baseline n = 593; follow-up n = 524) with a community (Malden, Massachusetts) that did not enforce the policy (baseline n = 636; follow-up n = 646); - Communities were matched with similar demographics, retail characteristics, and point-of-sale tobacco policies | - Youth access to and use of flavored tobacco products; - Change in inventory of flavored tobacco products before and after policy implementation | - In Lowell, the number of flavored tobacco products sold per retailer decreased from 77.3% to 7.3% (p <0.001); no significant change observed in Malden during same time frame; - Current use of any flavored product (excluding menthol and mint) by youth in Lowell decreased 2.4% (95% CI, −6.2–1.3, p >0.05) from baseline to follow-up and increased 3.3% (95% CI, −0.3–6.9, p >0.05) during the same time frame in Malden, resulting in a significant difference of −5.7% (95% CI, −10.7 to −0.7, p = 0.03) between the two communities; - Current use of any non-flavored tobacco product (including menthol and mint) by youth in Lowell decreased 1.9% (95% CI, −5.5–1.7, p >0.05) from baseline to follow-up and increased 4.3% (95% CI, 0.9–7.8, p <0.05) during the same time frame in Malden, resulting in a significant difference of −6.2% (95% CI, −11.0 to −1.4, p = 0.01) between the two communities; - No temporal precedence; baseline survey in Lowell occurred 1–3 months after policy implementation
Pearlman et al. (2019) | - Pre-post design with no control or comparison; - Cross-sectional, with two post-policy time points; - Evaluated outcomes of a comprehensive point-of-sale tobacco policy that restricted in January 2013 the sale of flavored tobacco products (excluding menthol) and discounts of tobacco product prices in Providence, Rhode Island; - Conducted store observation audits with retailer education in October 2017 (n = 90) and January 2018 (n = 82); - Conducted five rounds of retail compliance checks in November 2017 (round 1; n = 99) and during February–July 2018 (rounds 2–5; n = 408); - Collected data on the current use of tobacco products among 10th- and 12th-grade students from Annie E. Casey Evidence2Success Providence Youth Experience Survey:; – Pre-policy (2012): n = 2,150; – 3 years post-policy (2016): n = 2,062; – 5 years post-policy (2018): n = 2,223 | - Availability of both flavored and non-flavored tobacco products and tobacco price promotions at retail points of sale; - Determine whether citations for illegal sale of flavored tobacco products and tobacco price promotions increased with enforcement and then declined; - Examine whether enforcement of these policies decreased smoking among youth | - The availability of flavored products decreased by 24% from 2017 to 2018; - Of the 91 stores cited for a tobacco-sale-related violation:; – Violations for sales to an underage person decreased by 12%; – Violations for sales of flavored tobacco products to adults increased by 20%; – Violations for price discounting increased by 10%; – Current cigarette use was 3.2% (95% CI, 2.4–4.0) in 2012, 7.6% (95% CI, 6.3–9.0) in 2016, and 3.0% (95% CI, 2.1–3.8) in 2018; - Current use of any tobacco product declined from 22.2% (95% CI, 20.0–24.3) in 2016 to 12.1% (95% CI, 10.5–13.7) in 2018; - Cigar and cigarillo use decreased from 7.1% (95% CI, 5.7–8.5) in 2016 to 1.9% (95% CI, 1.2–2.6) in 2018; - E-cigarette use decreased from 13.3% (95% CI, 11.4–15.1) in 2016 to 6.6% (95% CI, 5.3–7.8) in 2018; - Hookah use decreased from 13.5% (95% CI, 11.6–15.3) in 2016 to 7.7% (95% CI, 6.4–9.2) in 2018
Rose et al. (2019) | - Data collected every 6 months from December 2011 to October 2016 from respondents, 18–34 years of age, in the Surveyed Truth Initiative Young Adult Cohort; - Young adults who smoked menthol cigarettes (n = 806) indicated responses if menthol cigarettes were not available; - Weighted analyses accounted for repeated measures and estimated prevalence and correlates of responses and trends over time | - Examined responses to hypothetical restrictions on menthol cigarettes among U.S. young adults who smoked menthol cigarettes | - Overall, 23.5% of young adults who smoked menthol cigarettes indicated that they would quit smoking if menthol cigarettes were not available (largely unchanged during 2011–2016); - In adjusted analyses, certain groups were more likely than other groups to indicate they would quit smoking if menthol restrictions were put in place:; – African American respondents: aOR = 2.16 (95% CI, 1.31–3.55); – Women: aOR = 2.21 (95% CI, 1.48–3.29); – Respondents with less than a high school education: aOR = 1.87 (95% CI, 1.01–3.48)
Bold et al. (2020) | - Novel empirical design to investigate within-person changes in smoking behaviors; - Recruited 29 non-treatment-seeking adults who smoked menthol cigarettes in Connecticut in 2017–2018: 15 females; 17 Black people, 10 White people, and 5 Hispanic people; - Used repeated-measures analyses to examine within-person changes in smoking behaviors when participants were switched from smoking their usual brands of menthol cigarettes to matched, nonmenthol brands of cigarettes for 2 weeks; - Participants returned for weekly visits for 4 weeks:; – Conducted a Timeline Follow-Back Interview at each visit; – Participants were asked to bring used cigarette filters; – Used biochemical measures to assess urine cotinine levels and menthol glucuronide as markers of recent menthol exposures | - Modeled the potential effects of a ban on menthol cigarettes on the smoking behaviors of people who currently smoked menthol cigarettes | - After switching to nonmenthol cigarettes, participants smoked a significantly fewer number of nonmenthol CPD than they did menthol cigarettes (mean decrease = 2.2 cigarettes; SD = 3.2; p <0.001), confirmed by significant reductions in cotinine levels in urine (p = 0.013); - After switching to nonmenthol cigarettes, participants had 18% lower scores of nicotine dependence (p <0.001) and greater increases in quitting motivation (mean increase = 2.1; SD = 2.8; p <0.001) and confidence (rated 1–10) (mean increase = 1.3, SD = 3.3, p = 0.04); - Exploratory analyses indicated significant interactions by race (p = 0.004): Reductions in the number CPD were greater among Black people who smoked (mean decrease = 3.5 cigarettes; SD = 2.8) than were reductions among non-Black people who smoked (mean decrease = 0.2; SD = 2.6)
Chaiton et al. (2020c) | - Pre-post, repeated longitudinal design with no control or comparison; - Examined effects before and after a ban of menthol-flavored tobacco products in January 2017 in Ontario, Canada, among adults (16 years of age or older) who reported current smoking (i.e., within the past 30 days) at baseline (September–December 2016) and completed follow-up (January–August 2018) (n = 913); - Poisson regression controlled for smoking and demographic characteristics at baseline | - Assessed relative rates of making a quit attempt and having quit smoking at follow-up | - People who reported smoking menthol cigarettes daily at baseline were more likely to report having quit smoking (aRR = 1.62; 95% CI, 1.08– 2.42) or having made a quit attempt (aRR = 1.25; 95% CI, 1.03–1.50) at follow-up than were people who reported smoking nonmenthol cigarettes at baseline
Rossheim et al. (2020) | - Pre-post, quasi-experimental design with no control or comparison; - Repeated cross-sectional, with elements of interrupted time series analysis and difference-in-difference designs; - Evaluated effects of FDA’s nationwide ban in 2009 on flavored cigarette products (excluding menthol) using data from the 2002–2017 National Survey on Drug Use and Health (n = 893,226); - Regression models were weighted for national representation | - Examined past-30-day use of cigarettes among youth (12–17 years of age), young adults (18–25 years of age), adults (26–49 years of age), and older adults (50 years of age or older) before and after implementation of FDA’s ban on flavored cigarettes | - Youth:; – 17% increase in the odds of reporting any current cigarette use immediately after the flavor ban (OR = 1.17; 95% CI, 1.07–1.29), and a 2.2% reduction, over the pre-ban trend, in the odds of reporting any cigarette use each quarter thereafter (OR = 0.98; 95% CI, 0.97–0.98); – Immediate 33% increase in the odds of reporting current use of menthol cigarettes (OR = 1.33; 95% CI, 1.15–1.54), and an additional 3.6% reduction, over the pre-ban trend, in the odds each quarter thereafter (OR = 0.96; 95% CI, 0.96–0.97); – The predicted probability of menthol use was reduced by 60%; - Young adults:; – Immediate 9% increase in the odds of reporting any current cigarette use (OR = 1.09; 95% CI, 1.03–1.16), and an additional 1.2% reduction, over the pre-ban trend, in the odds of cigarette use each quarter thereafter (OR = 0.99; 95% CI, 0.99–0.99); – Immediate 29% increase in the odds of reporting any current use of menthol cigarettes (OR = 1.29; 95% CI, 1.19–1.41), and a 2.6% reduction, over the pre-ban trend, in the odds of menthol cigarette use each quarter thereafter (OR = 0.97; 95% CI, 0.97–0.98); – The predicted probability of menthol use was reduced by 55%; - Adults and older adults:; – No significant differences were observed in either group for an immediate change after the flavor ban, and changes in slope were attenuated compared with the younger age groups: 0.25% reduction among adults and 0.5% reduction among older adults; – Estimated 17% immediate increase in the odds of past-30-day use of menthol cigarettes among adults (OR = 1.17; 95% CI, 1.06–1.30), with no corresponding reduction after the ban; – Among older adults, there was no statistically significant immediate increase in the past-30-day use of menthol cigarettes associated with the ban; reduction in the slope of past-30-day use of menthol cigarettes was attenuated (1.1%) after the ban
Yang et al. (2020) | - Post-only design with no control or comparison; - Cross-sectional study assessed the impact of one of the first comprehensive bans of all flavored tobacco products other than tobacco-flavored e-cigarettes among young adults in San Francisco, California, in January 2019; - Using Amazon Mechanical Turk, collected data from a sample of San Francisco residents, 18–34 years of age, who previously used tobacco products (n = 247); participants were surveyed about their tobacco use before and after the ban; - Used logistic regression models to estimate the odds, among the whole sample, of using flavored products after the flavor ban | - Assessed changes in the use of menthol cigarettes, e-cigarettes, and cigars among young adults | - 18- to 24-year-old group:; – Use of any tobacco products decreased by 17.7 percentage points (95% CI, −27.5 to −8.0) from 100% to 82.3%; – Use of any flavored tobacco products decreased by 11.3 percentage points (95% CI, −23.6–1.0) from 80.7% to 69.4%; - 25- to 34-year-old group:; – Use of any tobacco products decreased by 7.6 percentage points (95% CI, −11.4 to −3.7) from 100% to 92.4%; – Use of any flavored tobacco products decreased by 8.6 percentage points (95% CI, −14.0 to −3.3) from 84.9% to 76.2%
Chaiton et al. (2021a) | - Pre-post, repeated longitudinal design with no control or comparison; - Evaluated associations of a full ban on menthol cigarettes—implemented in January 2017 in Ontario, Canada—on smoking behaviors of people, 16 years of age or older, who currently smoked at baseline (September–December 2016; n = 1,821); follow-up survey conducted during January– August 2019 (n=810); - Used Poisson regression to assess probability of quitting smoking by menthol status before the ban, controlling for differences in smoking and demographic characteristics | - Evaluated quitting behavior 2 years after the ban on menthol | - Participants who smoked menthol cigarettes daily at baseline had a significantly higher likelihood of reporting having quit smoking than did participants who smoked nonmenthol cigarettes at baseline (aRR = 2.08; 95% CI, 1.20–3.61); - The probability of reporting more quit attempts increased significantly among participants who, at baseline, smoked menthol cigarettes daily (aRR = 1.45; 95% CI, 1.15–1.82) and occasionally (aRR = 1.27; 95% CI, 1.03–1.56) than it did among participants who, at baseline, smoked nonmenthol cigarettes
Guydish et al. (2021) | - Pre-post design with no control or comparison; - Examined the impact of a San Francisco, California (city and county) ban on the sale of all flavored tobacco products (including menthol cigarettes) among clients enrolled in residential substance use disorder treatment; - Three cross-sectional surveys were conducted at two residential substance use disorder facilities before the June 2018 ban was implemented and enforced (Wave 1: June 2018, n = 160) and after enforcement of the ban began in January 2019 (Wave 2: May 2019, n = 102; and Wave 3: November 2019, n = 120); - Multivariate regression analysis assessed changes in smoking behaviors across survey waves | - Assessed effects of ban on smoking behaviors, including number of CPD, quit attempts (for at least 24 hours) in the past year, and readiness to quit smoking (i.e., thinking of quitting smoking within the next 30 days) | - Survey respondents in Wave 2 (5 months post-ban implementation/ enforcement) who currently smoked cigarettes were less likely to have thought about quitting smoking in the next 30 days than respondents surveyed in Wave 1 (6 months pre-ban implementation/enforcement) (OR = 0.44; 95% CI, 0.29–0.67); survey respondents in Wave 3 (11 months post-ban implementation/enforcement) were less likely to have reported a past-year quit attempt than respondents surveyed in Wave 1 (OR = 0.80; 95% CI, 0.71–0.91); - Survey respondents in Wave 2 were less likely to have reported menthol as their usual type of cigarette (OR = 0.80; 95% CI, 0.72–0.90) than were survey respondents in Wave 1; survey respondents in Wave 3 were less likely to have smoked only menthol cigarettes in the past month than were survey respondents in Wave 1 (OR = 0.19; 95% CI, 0.18–0.19); - Among Wave 3 survey participants who currently smoked menthol cigarettes, 30.6% (n = 11) indicated that they had switched to smoking nonmenthol cigarettes and 16.7% (n = 6) reported smoking less because of the ban
Kingsley et al. (2021) | - Pre-post design, comparing two municipalities (Attleboro and Salem, Massachusetts) with restrictions on flavored tobacco products with a matched comparison municipality (Gloucester, Massachusetts) without restrictions on flavored tobacco products; - Cross-sectional surveys administered to high school students before (December 2015) (n = 2,432) and after (January or February 2018) (n = 2,814) policy implementation; - Focus groups conducted with high school students in each municipality in 2019 | - Assessed whether restrictions on flavored tobacco products in Massachusetts decreased tobacco use among youth over time and whether the length of policy implementation had a dose–response effect on tobacco-related outcomes | - Increases in current tobacco use among youth from baseline to follow-up were significantly smaller in the two municipalities with restrictions on flavored tobacco products than they were in the municipality without restrictions; - Difference-in-difference estimates of flavored (excluding menthol) tobacco use: −9.4%; 95% CI, −14.2% to −4.6%; - Difference-in-difference estimates of non-flavored (including menthol) tobacco use: −6.3%; 95% CI, −10.8% to −1.8%
Chung-Hall et al. (2022) | - Pre-post design; - Used longitudinal data from the Canadian arm of the 2016 and 2018 International Tobacco Control Four Country Smoking and Vaping Survey, which surveyed before and after a ban on menthol cigarettes was implemented in seven Canadian provinces (n = 1, 236); - At baseline, 1,098 people smoked nonmenthol cigarettes and 138 people smoked menthol cigarettes; - Used multivariate logistic regression models to examine associations between smoking behaviors before and after the bans on menthol cigarettes | - Evaluated the impact of bans on menthol cigarettes on differences in quit attempts and quitting smoking between people who smoked menthol and nonmenthol cigarettes at baseline | - At follow-up, 59.1% of people who had smoked menthol cigarettes before the ban switched to smoking nonmenthol cigarettes after the ban; 21.5% quit smoking; and 19.5% continued smoking menthol cigarettes, which were purchased primarily from First Nations reserves; - Those who smoked menthol cigarettes were more likely than those who smoked nonmenthol cigarettes to make a quit attempt (aOR = 1.61; 95% CI, 1.03–2.51) and to remain quit (aOR = 2.30; 95% CI, 1.06–5.01); - Quit success did not differ significantly between those who smoked menthol cigarettes and those who smoked nonmenthol cigarettes (aOR = 1.72; 95% CI, 0.98–3.01); - People who smoked menthol cigarettes daily were more likely to quit smoking than were people who smoked nonmenthol cigarettes daily (aOR = 2.21; 95% CI, 1.15–4.24), and people who smoked menthol cigarettes daily and quit before the ban were more likely to remain quit than were people who smoked nonmenthol cigarettes daily (aOR = 2.81; 95% CI, 1.15–6.85); - Non-White participants were more likely to make a quit attempt after the ban than were White participants (aOR = 1.77; 95% CI, 1.10–2.85)
Fong et al. (2022) | - Pre-post design; - Pooled data from two pre-post cohort studies conducted in seven Canadian provinces:; – Ontario Menthol Ban Study: 1,084 adults who smoked, including 295 people who smoked mainly menthol cigarettes before the ban on menthol-flavored tobacco products; – International Tobacco Control Policy Evaluation Canada Survey: 1,236 adults who smoked, including 128 people who smoked mainly menthol cigarettes before the ban on menthol-flavored tobacco products; - Used weighted multivariable logistic analyses to compare quit success, after a ban on menthol-cigarettes, among people who smoked menthol cigarettes and people who smoked nonmenthol cigarettes (for daily smoking and for all smoking); controlled for sex, age, ethnicity, education, baseline smoking status, baseline number of cigarettes smoked per day, and study region; - Projections to the United States were created by multiplying the effect size of the Canadian menthol ban on quitting by the number of people who smoked menthol cigarettes overall and by the number of African American people from the 2019 National Survey on Drug Use and Health | - Estimated the impact of Canada’s menthol ban on quitting smoking and applied the estimates to project the impact of such a ban on menthol in the United States | - After the ban, people who smoked menthol cigarettes at baseline were more likely to quit smoking than people who smoked nonmenthol cigarettes at baseline among those who smoked daily (difference = 8.0%; 95% CI, 2.4–13.7%) and all those who smoked (difference = 7.3%; 95% CI, 2.1–12.5%); - The projected number of people who would quit smoking after such a menthol ban in the United States was 789,724 people who smoked daily (including 199,732 African American people) and 1,337,988 total people who smoked (including 381,272 African American people)
Kyriakos et al. (2022) | - Pre-post design; - Data from the International Tobacco Control Netherlands Surveys (February–March 2020, September–November 2020, and June–July 2021) of 1,326 adults, 18 years of age and older, who smoked before and after the European Union’s ban on menthol cigarettes in May 2020; - Conducted weighted, bivariate logistic regression and generalized estimating equation model analyses | - Evaluated the impact of the ban on menthol as a characterizing flavor in cigarettes on smoking cessation outcomes | - People who smoked menthol cigarettes before the ban had greater odds of making a quit attempt after the ban than those who smoked nonmenthol cigarettes (66.9% vs. 49.6%, respectively; aOR = 1.89; 95% CI, 1.13–3.16); - Women who smoked menthol cigarettes before the ban had greater odds of quitting by Wave 3 of data collection than did women who smoked nonmenthol cigarettes (aOR = 2.23, 95% CI, 1.10–4.51)
Olson et al. (2022a) | - Pre-post design; - Examined data from two surveys (Minnesota Youth Tobacco Survey and the Minnesota Student Survey) of in Minneapolis and St. Paul, Minnesota (Twin Cities) and in the rest of the state of Minnesota before and after the implementation of sales restrictions on all flavored tobacco products in 2016 and of restrictions expanded to include menthol tobacco products in 2018 | - Assessed changes in the prevalence of tobacco use among youth in Minnesota before and after policies that restricted the sales of all flavored tobacco products and of menthol tobacco products | - According to the Minnesota Youth Tobacco Survey, use of any tobacco product did not change significantly among youth in the Twin Cities after the flavor policies were implemented, but increased 26% (from 12.4% to 15.7%; p <0.05) among youth in the rest of the state of Minnesota; - According to the Minnesota Student Survey, use of any tobacco product by youth increased to a greater extent in the rest of the state (from 13.9% to 20.1%; or by 44.6%) than it did in the Twin Cities (from 12.2% to 16.5%, or by 34.6%) after the flavor policies were implemented

Notes: aOR = adjusted odds ratio; aRR = adjusted risk ratio; CI = confidence interval; CPD = cigarettes smoked per day; FDA = U.S. Food and Drug Administration; FTC = Federal Trade Commission; OR = odds ratio; RR = risk ratio; SD = standard deviation.

Policies prohibiting the sale of flavored products vary in their comprehensiveness, and some evaluation studies have limitations, including lack of a control or comparison group, post-only designs, and limited sampling of population groups of interest. However, when considered in context with studies of the impact of the U.S. prohibition on characterizing flavors other than menthol and tobacco in cigarettes (Courtemanche et al. 2017), these studies of local, state, and Canadian flavor restrictions provide strong additional support for eliminating flavors to reduce use of tobacco products. This is likely to particularly benefit population groups with disproportionate prevalence of tobacco use and tobacco-related health disparities during both adolescence and young adulthood, the period when initiation and progression to regular use is most likely to occur (USDHHS 2012; Federal Register 2022b). Further policy evaluation studies will help assess the extent to which this type of regulation reduces tobacco-related health disparities.

Despite the lack of studies to date that have directly assessed the impact of policies banning flavored tobacco products on tobacco-related health disparities in the United States, it is expected that eliminating menthol cigarettes in the United States would reduce tobacco use and, correspondingly, reduce tobacco-related health disparities in youth and other population groups that use menthol cigarettes at high rates, such as Black or African American people (FDA 2022c) (see Chapter 2).

FDA has found that, although there is little evidence to suggest that menthol cigarettes are more toxic than other cigarettes, prohibiting menthol as a characterizing flavor in cigarettes will provide substantial public health benefits because menthol cigarettes facilitate initiation and regular use and make quitting more difficult (FDA 2013, 2022a). FDA’s Tobacco Products Scientific Advisory Committee concluded that removing menthol cigarettes from the marketplace would benefit public health, and the WHO recommends that countries ban menthol in cigarettes, including menthol analogues, precursors, and derivatives, and consider prohibiting menthol in products other than cigarettes (Tobacco Products Scientific Advisory Committee 2011; WHO 2016a). As of March 31, 2023, approximately 20% of the U.S. population was covered by state or local-level policies that restrict the sales of all types of flavors across most tobacco products, including menthol cigarettes (Truth Initiative 2023). As noted by FDA, its proposed rules to prohibit menthol cigarettes and flavored cigars nationwide “represent an important step to advance health equity by significantly reducing tobacco-related health disparities” (FDA 2022a).

Several U.S. surveys show that large percentages of young adults and adults who smoke menthol cigarettes reported an intention to quit if menthol cigarettes were no longer sold (WHO 2016a; Wackowski et al. 2018; Cadham et al. 2020). Among young adults and adults who smoke menthol cigarettes, a greater percentage of Black people as compared with White people reported that they would not switch to unflavored cigarettes if menthol cigarettes were no longer available (Hymowitz et al. 1995; Rose et al. 2019; Cadham et al. 2020). A 2010 survey found the strongest support for prohibiting menthol cigarettes, and strong intentions to quit smoking if menthol cigarettes were no longer available, among population groups with the highest prevalence of menthol cigarette use (Pearson et al. 2012). A 2018 survey found that an estimated 28% of people who use menthol cigarettes support eliminating menthol cigarettes, with even broader support among population groups that have been targeted by tobacco industry marketing—such as non-Hispanic African American people and people with lower educational attainment—regardless of smoking status (Czaplicki et al. 2022). A 2021 survey found that 62% of adults surveyed supported a policy prohibiting the sale of menthol cigarettes, including more than one-third of respondents who currently used tobacco products, including menthol cigarettes (Al-Shawaf et al. 2023).

In a small experimental study of 29 adults who currently smoked menthol cigarettes and were not trying to quit, participants were switched to a matched-brand nonmenthol cigarette to model a potential removal of menthol cigarettes from the market. After switching to nonmenthol cigarettes, participants had significantly lower nicotine dependence scores and greater increases in quitting motivation and confidence in their ability to quit smoking. In exploratory analyses, a significant interaction between race and changes in cigarettes per day was observed with results indicating greater reductions in cigarettes smoked per day among Black adults compared with “non-Black” adults (Bold et al. 2020).

A study by Chung-Hall and colleagues (2022) used longitudinal data from the Canadian arm of the International Tobacco Control (ITC) Four Country Smoking and Vaping Survey to evaluate the effects of menthol cigarette sales restrictions in seven Canadian provinces. The sample included a total of 1,236 adults who smoked and were contacted in both 2016 (pre-sales restrictions) and 2018 (post-sales restrictions), including 1,098 adults who smoked nonmenthol cigarettes and 138 adults who smoked menthol cigarettes at baseline. Results showed that people who smoked menthol at baseline were significantly more likely to make a quit attempt at follow-up than those who smoked nonmenthol cigarettes; however, there were no significant differences in short-term quitting after the menthol sales restrictions were implemented between people who did and did not smoke menthol cigarettes at baseline. Additionally, people characterized as “non-White” in the study were more likely than White people to make a quit attempt (Chung-Hall et al. 2022).

A 2022 study used pooled data from two pre–post cohort studies assessing the impact of Canada’s menthol cigarette ban in seven provinces and Ontario’s earlier menthol cigarette ban to estimate the potential impact of FDA’s proposed rule prohibiting menthol as a characterizing flavor in cigarettes in the United States (Fong et al. 2022). On the basis of the pooled Canadian data, 22.3% of adults who smoked mainly menthol cigarettes and 15.0% of adults who smoked nonmenthol cigarettes quit smoking between the pre- and post-surveys. Using these estimates, the authors projected that, if FDA’s proposed rule prohibiting menthol in cigarettes was implemented, an estimated 1.3 million people would quit smoking cigarettes, 381,272 of whom would be Black people who smoke.

A 2022 study assessing the impact in the Netherlands of the European Union’s 2020 menthol cigarette ban using data from the 2020–2021 ITC Netherlands Survey found that people who smoked menthol cigarettes were significantly more likely to make a quit attempt than those who smoked nonmenthol cigarettes (Kyriakos et al. 2022). The data on increased odds of successfully quitting among those who smoked menthol cigarettes were not statistically significant, likely due to limited sample size; however, the quit rates observed in the Netherlands were higher than in Canada, as reported by Chung-Hall and colleagues (2022). The authors explained that because quit rates were highest among women who smoked menthol cigarettes and because the odds of making a quit attempt were higher for people who smoked menthol cigarettes who were young adults, people who smoked daily, or people who had higher nicotine dependence, the policy may have been most successful among population groups of highest risk and may help advance equity (Kyriakos et al. 2022).

Chapter 6 gives detailed descriptions of simulation models to assess the potential impact of prohibiting menthol cigarettes, as well as the effects of menthol cigarettes on the prevalence of smoking, premature deaths, and life-years lost among the general population and among Black or African American people specifically (Levy et al. 2011, 2023; Mendez 2011; Le and Mendez 2021; Mendez and Le 2021; Issabakhsh et al. 2022). The simulation models and the policy evaluation data discussed earlier (showing reductions in sales, reductions in tobacco product use, and increased intentions to quit) show that eliminating flavors, including menthol, in tobacco products would likely reduce disparities in smoking prevalence and quitting. There also is strong evidence to support the conclusion that the elimination of menthol cigarettes in the United States would reduce health disparities, given the substantial differences in menthol cigarette use prevalence and the resulting disproportionate number of premature deaths among specific population groups. As with other evidence-based tobacco control strategies, implementation of policies to prohibit the sale of flavored tobacco products as part of comprehensive tobacco control programs could amplify the public health impact of the policies overall as well as their ability to address tobacco-related disparities (USDHHS 2012; NCI 2017b).

#### Summary and Recommendations

Several components of FDA’s regulatory authority can help to increase awareness, understanding, and appreciation of the harms of tobacco, reduce initiation, increase intention to quit cigarette smoking, increase quitting, and improve overall health outcomes. Requiring pictorial health warnings on cigarette packages and advertisements increases both understanding of the harms of smoking and intention to quit among different population groups. Reducing the level of nicotine in tobacco products to minimally or nonaddictive levels would reduce cigarette consumption among many different population groups and may improve cessation outcomes. For example, there is some evidence that reduced-nicotine-content cigarettes resulted in increased cessation among people with mood and/or anxiety disorders compared to usual cigarettes. In addition, eliminating flavors in tobacco products—particularly menthol cigarettes—is expected to reduce tobacco initiation, increase quitting, and improve overall health outcomes among certain population groups. Further, as noted in Chapter 3, the scientific evidence to justify prohibiting the marketing, sales, and distribution of menthol tobacco products and flavored cigars has been both substantial and sufficient for years.

Further analysis of how marketing authorizations, product regulations, and implementation strategies affect specific outcomes along the tobacco use continuum from exposure to secondhand tobacco smoke to health outcomes is warranted. In addition, ongoing monitoring of tobacco product marketing, its impact on the use of products by people who experience tobacco-related health disparities, and the related health consequences is critical. Ensuring that surveillance systems collect disaggregated data would provide a better understanding of specific tobacco product use among population groups and the risks and benefits for all.

### Place-Based and Product-Focused Retail Policies

In its blueprint to end the U.S. tobacco epidemic, IOM (now the National Academy of Medicine) recommended that governments develop, implement, and evaluate legal mechanisms for restricting the number of tobacco outlets and for restructuring tobacco sales (IOM 2007). To that end, policy interventions to regulate the retail environment (beyond long-standing tax policies) have increased at both the state and local levels and are being adopted by territories and tribes (David et al. 2013; Luke et al. 2016; CounterTobacco.org n.d.b). These strategies may reduce the prevalence of tobacco use as well as disparities in tobacco use and tobacco-related disease and death among population groups (Kong and King 2021). This section examines strategies that are organized into two broad categories: place-based policies and product-focused policies. The place-based policies discussed in this report are supply-side interventions that limit which types of retailers can sell tobacco products, where those retailers can be located, and how many retailers can sell these products. The product-focused policies, in turn, are intended to suppress demand for tobacco by increasing the price for these products through tax and non-tax mechanisms and by regulating what products are sold.

Some jurisdictions have both place-based and product-focused policies. For example, in 2008, San Francisco became the first city to mandate tobacco-free pharmacies (i.e., pharmacies that do not sell tobacco products) and, in 2014, the city set a cap on the number of tobacco sales permits allowed in each of its 11 districts, aiming to reduce disparities in retailer density in lower income neighborhoods and neighborhoods with a high proportion of people from minoritized racial and ethnic groups (San Francisco Tobacco-Free Project 2016; CounterTobacco.org n.d.a). In 2018, San Francisco also prohibited the sale of flavored tobacco products, including menthol products (Public Health Law Center 2018a; San Francisco Tobacco Free Project n.d.). The long-term goal of these interventions is to reduce the concentration of tobacco retailers in socioeconomically disadvantaged areas and ultimately to reduce tobacco use (Rodriguez et al. 2013; Lee et al. 2017).

Retail-based policies use multiple mechanisms to prevent the initiation of tobacco and reduce its use. By reducing the number of tobacco retailers, place-based interventions increase the time and resources needed to obtain tobacco products (IOM 2007). In addition, a reduced concentration of tobacco retailers diminishes residents’ exposure to tobacco advertising and product displays, which are linked to smoking initiation (Robertson et al. 2015); nicotine cravings and withdrawal symptoms (Carter et al. 2009; Kirchner et al. 2013); lower self-efficacy to quit among people who smoke (Chaiton et al. 2014); unplanned or impulse purchases of tobacco (Germain et al. 2010; Clattenburg et al. 2013; Kim et al. 2014); and the diversion of money needed for household essentials (such as food or rent) to tobacco product purchases, resulting in a lack of funds for such household essentials (known as “smoking-induced deprivation”) (NCI and WHO 2016; Siahpush et al. 2016).

Product-focused interventions that increase the price of tobacco products or prohibit the sale of tobacco products also reduce consumption, promote quitting, and prevent smoking relapse, as well as reduce smoking-induced deprivation among those who quit smoking (Chaloupka et al. 2012; NCI and WHO 2016; Nonnemaker et al. 2016). In addition, establishing minimum prices for tobacco products may reduce variation in purchase patterns within and between product categories (e.g., little cigars or cigarillos and cigarettes), which would limit opportunities of those who use tobacco products to engage in price-minimizing strategies, like buying cheaper products instead of quitting (Golden et al. 2016).

Indirect effects are also plausible. For example, environments with reduced retail availability (such as limits on the type, location, number, or concentration of retailers) and reduced access to products (such as restrictions on the sale of flavored tobacco products) may contribute to denormalization of commercial tobacco in the community (Zhu et al. 2007; McDaniel and Malone 2014; Smith et al. 2017). Zhu and colleagues (2007) compared quit ratios among first-generation immigrants in California from China and Korea with quit ratios among (a) the general population in California and (b) people living in China and Korea. Social norms regarding smoking are vastly different in China and Korea than in California. Results showed that, among people who had ever smoked, quit ratios were comparable between Chinese (52.5%) and Korean (51.1%) first-generation immigrants and the general population (53.3%). However, quit ratios among these immigrant populations were substantially higher than previously reported quit ratios among people in the respective countries (China: 11.5%; Korea: 22.3%). These findings suggest that significant changes in social norms toward smoking can improve cessation at the population level (Zhu et al. 2007).

Furthermore, McDaniel and Malone (2014) conducted 15 focus groups with patrons (n = 84) of retail outlets (grocery stores and pharmacies) that had voluntarily discontinued sales of tobacco products across California, New York, and Ohio to understand normative beliefs around where cigarettes should or should not be sold. Some participants considered cigarettes to be integral to the identity of certain types of retail outlets, specifically convenience stores, whereas it may be inappropriate for other types of retailers, such as pharmacies and grocery stores focused on selling healthy products, stores that are frequented by children, or those selling products for children, to sell tobacco products. Evidence from the evaluation of the California Department of Public Health, California Tobacco Control Program—which utilized a social norm change approach to reduce tobacco use—found that this program was associated with reductions in the overall adult smoking prevalence (from 22.7% in 1988 to 13.8% in 2007), a shift away from daily and/or heavy smoking, and a consistently lower prevalence of smoking among adolescents in California than among adolescents across the nation (Roeseler and Burns 2010). Thus, interventions that change norms in this way can discourage initiation and improve cessation outcomes (Roeseler and Burns 2010).

This section reviews evidence on the benefits of place-based strategies and selected product-focused strategies. The evidence reviewed uses multiple approaches, including (1) evaluations of actual policies; (2) computational modeling and other simulations of hypothetical policies; and (3) experimental manipulations of policy conditions in controlled settings, including both real-world and virtual settings (Kim et al. 2013; Shadel et al. 2016). This review considered evidence of policy effects on outcomes related to the tobacco retail environment, product acquisition, and tobacco use (e.g., reductions in retailers, changes in purchase behaviors, reduced tobacco use prevalence, and cessation-related outcomes).

Retail policies are a complement to long-standing evidence-based tobacco control interventions and are well suited to addressing tobacco-related health disparities because, although the prevalence of smoking in the United States has declined, the number of tobacco retailers has increased (Golden et al. 2022). In general, tobacco retailers are disproportionately clustered in lower income neighborhoods and in neighborhoods with a high proportion of minoritized racial and ethnic groups and of youth and young adults (Fakunle et al. 2019; Berg et al. 2020; Kong et al. 2021; Golden et al. 2022). Furthermore, there is greater advertising of tobacco products in the interior and on the exterior of tobacco retail stores in those neighborhoods (Lee et al. 2015; Rose et al. 2022a). However, the evidence regarding vape shops density is mixed, which may be due, in part, to the different ways in which vape shops are defined (Lee et al. 2018a), as covered in Chapter 5 of this report. Chapter 5 of this report also covers the influence of the tobacco retail environment on tobacco-related health disparities in greater detail. These inequities are not simply the result of consumer demand but are associated with discriminatory housing policies such as redlining and targeted industry marketing in communities specifically identified by the industry as “focus” communities (see “Influences of the Tobacco Retail Environment” in Chapter 5) (Kool USA 2002, 2003; Cruz et al. 2010).

Retail policies may have a greater impact when combined with each other (Luke et al. 2017; Kong et al. 2021; Golden et al. 2022). Indicators of the pro-equity effects of tobacco retail policy interventions include reduced economic, racial and ethnic, or other disparities in the retail availability of tobacco products; reduced exposure to product advertisements and displays; and reduced sale or use of tobacco products. This review highlights what is known about the effects of tobacco retail policy interventions for population groups experiencing tobacco-related disparities.

#### Place-Based Strategies

State and local policy strategies aim to limit the type, location, and quantity of tobacco retailers. Common mechanisms that have been used to do so include, but are not limited to, (1) mandating that pharmacies be tobacco-free, (2) restricting tobacco sales near schools, and (3) adopting other strategies to reduce the number of retailers (such as maximizing the distance between retailers and placing caps on the number of retailers in a region, usually through the use of tobacco retailer licensing). These specific place-based strategies are described in the following sections.

##### Tobacco-Free Pharmacies

In 2012, tobacco sales in U.S. pharmacies totaled almost $5 billion (U.S. Census Bureau 2012), even though selling tobacco is incompatible with the mission of pharmacies to promote health and wellness. Pharmacies’ tacit approval of the purchase of tobacco products may send mixed messages to consumers and normalize tobacco use (Hudmon et al. 2006). A 2014 assessment of a random sample of tobacco retail outlets in North Carolina, including pharmacies, showed that most (91.7%) pharmacies selling e-cigarettes placed them behind the counter (versus in front of or on top of the counter or in multiple locations); all pharmacies assessed that sold e-cigarettes placed them with cessation medications, even though e-cigarettes are not approved by the FDA as cessation products (Wagoner et al. 2018).

Evidence that pharmacies sell cigarettes at lower prices and offer more cigarette sales promotions than do other types of tobacco retailers raises additional public health concerns (Henriksen et al. 2016; Seidenberg et al. 2022). Between 2005 and 2009, cigarettes sales in U.S. pharmacies increased, but total cigarette sales decreased during this time (Seidenberg et al. 2012). Although pharmacies may not violate laws prohibiting tobacco sales to people who are underage as often as some other types of retailers (Wheeler et al. 2021), a study of FDA retail inspection data from 2012 and 2017 showed that pharmacies failed 7.7% of inspections for selling tobacco products to underage people (Lee et al. 2018b).

The Tobacco Control Act precludes FDA from prohibiting tobacco sales in any specific category of retail outlets, including pharmacies, but the Act expressly preserves state, territorial, tribal, and local authority to regulate or prohibit the sale of tobacco products (Family Smoking Prevention and Tobacco Control Act 2009; FDA 2018a). Tobacco-free pharmacy policies have the potential to reduce the number of tobacco retailers in a community (Jin et al. 2016b). This section describes results from simulation studies and empirical studies of the impact of tobacco-free pharmacies on retailer density and disparities.

Five of the studies identified by the literature search used simulation modeling to estimate the potential outcomes of a tobacco-free pharmacy policy aimed at reducing the density of tobacco retailers in U.S. jurisdictions where a policy had not yet been implemented (Myers et al. 2015; Tucker-Seeley et al. 2016; Luke et al. 2017; Craigmile et al. 2021; Bourke et al. 2022). According to three of these simulations, having tobacco-free pharmacies would yield a 10% reduction in the total number of tobacco retailers in Rhode Island (Tucker-Seeley et al. 2016), a 14% reduction in the density of tobacco retailers in North Carolina (Myers et al. 2015), and a 3.5% reduction in the density of tobacco retailers in Wilmington, Delaware (Bourke et al. 2022). Another simulation study estimated the impact of policy options to reduce the density of tobacco retailers in four archetypical and abstract town types (higher versus lower income and urban versus suburban towns). The model showed a greater effect in reducing the availability of cigarettes from establishing tobacco-free pharmacies than from a random reduction in tobacco retailers (Luke et al. 2017).

Two of the identified simulation models examined the impact of tobacco-free pharmacies on disparities in retailer density. Luke and colleagues’ (2017) model did not project a greater effect in communities where tobacco retailers are disproportionately located. However, a study that simulated the impact of prohibiting all pharmacies in Ohio from selling tobacco products found that such a policy would increase disparities; that is, census tracts with the largest prevalence of African American people would experience smaller reductions in the concentration of tobacco retailers than other census tracts (Craigmile et al. 2021).

Evidence from simulation modeling studies may underestimate actual declines over time in the density of tobacco retailers (Jin et al. 2016b). For example, evaluation studies from Massachusetts and California showed that reductions in the density of tobacco retailers over 8–10 years were 1.44 times larger in cities with tobacco-free pharmacies as they were in cities without tobacco-free pharmacies (Jin et al. 2016a,b). These policies may serve as a tipping point for other density-reduction strategies and contribute to the establishment of community norms that reduce demand for tobacco products.

In 2014, CVS Pharmacy discontinued tobacco sales in its 7,600 U.S. pharmacy stores (PR Newswire 2014; Tobacco Control Legal Consortium 2014b). After the voluntary policy was implemented, households that purchased cigarettes from CVS exclusively were 38% more likely to stop purchasing cigarettes than households that purchased cigarettes from other pharmacies. A small but statistically significant decline in pack sales (a decline of 0.14 packs per month per person who smoked) was found in states where CVS had a market share of at least 15% compared with states with no CVS stores (Polinski et al. 2017).

One study found that the impact of CVS’s policy in the Southeastern United States, an area with disproportionately high tobacco use, was confounded by the decision of two large dollar-store chains to begin selling tobacco products (Hall et al. 2019a). Another study conducted after CVS implemented its policy analyzed quit attempts among adults who smoked. It found that the CVS policy had a greater impact on quit attempts in urban counties than in rural counties, likely owing to the higher concentration of CVS stores in urban areas (Ali et al. 2020). These studies suggest that policies that are more comprehensive, perhaps in conjunction with other retail strategies, may have a broader impact on reducing tobacco use.

Whether tobacco-free pharmacies have the potential to reduce disparities in tobacco retailer density appears to depend on the sociodemographic characteristics of the neighborhoods in which the pharmacies are located (Smith et al. 2020). In New York City, for example, a law prohibiting the sale of tobacco products in pharmacies resulted in an average decrease in retailer density of 6.8% across neighborhoods. However, neighborhoods with a higher proportion of non-Hispanic White residents and neighborhoods with higher median household incomes benefited the most from the policy because pharmacies that sold tobacco made up a greater proportion of tobacco retailers in those neighborhoods (Giovenco et al. 2019). Further, an analysis of the impact of CVS’s removal of tobacco in Rhode Island found that the CVS policy did not impact racial, ethnic, and socioeconomic disparities in retailer density. Further, in a prospective analysis within the same study, the authors concluded that a ban on all tobacco sales in pharmacies would not significantly reduce the disparate concentration of tobacco retailers in census tracts with higher proportions of African American or Black residents, Hispanic residents, or families living in poverty (Tucker-Seeley et al. 2016).

In summary, tobacco-free pharmacy policies on their own may not decrease the number of tobacco retailers equitably across neighborhoods because there are lower odds that pharmacies that sell tobacco are located in neighborhoods with a greater percentage of Black residents or Hispanic or Latino residents (Kong et al. 2022). Most studies that have examined tobacco-free pharmacy policies have simulated impacts of hypothetical policies. Massachusetts and New York have statewide tobacco-free pharmacy laws, and many localities in California, Massachusetts, New York, and Minnesota require tobacco-free pharmacies, but their impact on tobacco use among people experiencing disparities remains to be studied.

Most licensed pharmacists and adults support prohibiting tobacco sales in pharmacies, and studies suggest that such policies would not affect customer visits to pharmacies and potentially could result in increased sales of NRTs (Hudmon et al. 2006; Smith et al. 2012; Journal of the American Pharmacists Association 2015; Wang et al. 2016; Pimentel and Apollonio 2019; Truth Initiative 2019b; Glasser and Roberts 2021). Eliminating tobacco product sales in pharmacies could foster tobacco-free norms and remove a retail source of cheaper cigarettes. The effects of combining tobacco-free pharmacy policies with other retail strategies on tobacco use by groups experiencing tobacco-related health disparities warrants investigation.

##### Restricting Tobacco Sales Near Schools

Another strategy to reduce the number of tobacco retailers that has been explored in the literature is to restrict the proximity of retailers to schools and other locations where youth congregate, such as youth centers and playgrounds. This type of policy could help address tobacco-related health disparities, particularly among youth who walk to or from school. As described in detail in Chapter 5 of this report, studies suggest that the prevalence of smoking among youth is higher in neighborhoods with higher densities of tobacco retailers (Novak et al. 2006; Henriksen et al. 2008; Trapl et al. 2021a). In this case, proximity refers to the number of feet or meters between a tobacco retailer’s geographic location and the nearest border of a primary or secondary school campus. For example, more than 50 cities or counties in California restrict the sale of tobacco near schools, although the minimum distance required and measurement method (by a straight line or roadway) and definitions of schools differ among local policies (California Department of Public Health 2016). Local ordinances in the United States vary in the required distance between a tobacco retailer and a school, and often have 500-foot, 1,000-foot, or 1,500-foot buffers (Coxe et al. 2014; Myers et al. 2015; Luke et al. 2017).

Nearly all studies of the impact of restricting tobacco retailers near schools are simulation models, as described later in this chapter. However, one empirical study of Philadelphia’s policy to reduce retailer licenses found that, 3 years after implementation, the prohibition on new tobacco retailers within 500 feet of schools benefited 84,300 youth from more than 200 schools, including 10,500 youth from 32 schools who no longer had any tobacco retailers located within 500 feet of their schools. There was no evidence of differences in impact between low-income schools and not-low-income schools (Lawman et al. 2020).

Studies that have assessed the impact of imposing hypothetical restrictions on the proximity of tobacco retailers to schools feature unique assumptions and varying distance thresholds for proximity to schools, but all of them suggest that school proximity requirements could benefit public health. A modeling study focused on North Carolina concluded that a state-level restriction on the sale of tobacco products within 1,000 feet of schools would reduce the number of retailers by 17.8% (Myers et al. 2015). The study found that a tobacco-free pharmacy law combined with a policy limiting sales near schools would result in the greatest reduction in retailers (29.3%) (Myers et al. 2015). Another study modeled the potential impacts of four policies in Wilmington, Delaware: a tobacco-free pharmacy law, a law that capped the number of retailers overall, a law that set a limit of one retailer per 1,000 residents, and a law that prohibited tobacco sales within 500 meters of a school (Bourke et al. 2022). This study estimated that the school proximity policy would be the most effective policy to reduce tobacco retailer density overall (78.2%) and in medium- and high-density residential zones (73.3%), and that average resident-to-retailer distance would increase by 115% overall and by 141.5% in medium- and high-density residential zones.

Pro-equity effects of school proximity policies were evident in simulation studies that examined this issue. Results from the Tobacco Town agent-based simulation model suggested that 500-foot, 1,000-foot, and 1,500-foot restrictions from schools would all reduce the density of tobacco retailers and increase the cost of accessing tobacco (including travel time), with greater effects seen at greater distances (Luke et al. 2017). This model also suggested that restricting the proximity of retailers to schools is more effective at reducing the concentration of tobacco retailers in dense, urban areas and is particularly effective in lower income, urban areas; thus, distance requirements have the potential to have an impact in neighborhoods with population groups experiencing tobacco-related health disparities (Luke et al. 2017). Statistical models focused on New York City and Missouri suggest that implementing a simulated ban on tobacco sales within 1,000 feet of schools would either reduce or eliminate existing disparities in the density of tobacco retailers in predominantly lower income, African American, and Hispanic neighborhoods compared with predominantly higher income and White neighborhoods (Ribisl et al. 2017). A simulation of a policy using licensing laws to eliminate tobacco retailers from within 1,000 feet of all schools in Ohio predicted that the policy would be most effective in lower income, African American, and urban neighborhoods (Craigmile et al. 2021).

These studies suggest that reducing tobacco retailers, including vape shops, near schools may result in a reduction in retailers in neighborhoods with people experiencing tobacco-related health disparities (Chido-Amajuoyi et al. 2020). Tobacco retailer licensing laws require businesses to obtain a license in exchange for the privilege to sell tobacco products. Using a licensing law, such as the one in Philadelphia, as a mechanism to track retailers and implement and enforce this type of policy may help bolster compliance (Mistry et al. 2015; Wang et al. 2017; Lawman et al. 2020; Craigmile et al. 2021). This retailer reduction policy may also indirectly benefit public health by reducing tobacco use among adults who live near schools and experience tobacco-related health disparities (Rogers and Vargas 2018).

##### Retailer-to-Retailer Proximity Restrictions and Caps on Quantity of Retailers

Policies that maximize the distance between tobacco retailers or that cap the number of retailers in a community are intended to reduce retailer density. A systematic review and meta-analysis identified 37 empirical studies published from eight countries (Australia, Canada, Denmark, England, Finland, New Zealand, Scotland, and the United States) from 2000 through October 2020 (Lee et al. 2022). Analysis of pooled results indicate that reducing the density and proximity of tobacco retailers is consistently associated with reductions in tobacco use among adults and likely will result in improvements in population health, complementing other studies describing the relationship between tobacco retailer density and proximity with tobacco use among youth (Lee et al. 2022).

An empirical study by Lawman and colleagues (2020) showed that 3 years after Philadelphia changed its tobacco retailer licensing law to allow—through attrition—a maximum of only one tobacco retailer per 1,000 people for each of 18 city planning districts, the city observed a 20.3% reduction in the number of retailers. Its reductions in tobacco retailer density were significantly greater in lower income districts than in higher income districts, suggesting that this type of retailer reduction policy could reduce the availability of tobacco and consequent tobacco marketing and advertising in lower SES communities where residents may have reduced access to healthcare and cessation support (Lawman et al. 2020).

Simulation studies also examined proximity restrictions and strategies to cap the quantity of tobacco retailers. As discussed previously, in North Carolina, a modeling study estimated that imposing a minimum distance of 500 feet between tobacco retailers would reduce the total number of retailers by 22.1% at the state level (Myers et al. 2015). The Tobacco Town agent-based simulation model analyzed different policy interventions in four archetypal and abstract town types (a combination of urban–suburban and lower–higher income communities) and found that the effect of different policies will vary according to town type and that implementing multiple policies may be more effective than just one policy on its own (Luke et al. 2017). For example, retailer-to-retailer proximity restrictions with larger distances between retailers had a greater impact in reducing tobacco retailers in lower income urban communities, whereas capping the number of licenses at 50% of the current total had a greater impact in higher income suburban settings (Luke et al. 2017).

A modeling study from New Zealand found that capping the number of retailers would result in reduced tobacco use and tobacco-related disease, increased quality-adjusted life years, and cost savings for the healthcare system. The authors noted that the retailer cap policy would be expected to yield five times greater per capita quality-adjusted life years for Māori people (the indigenous population in New Zealand, which has a higher smoking prevalence and estimated higher price sensitivity compared with other population groups) and could be combined with other policies, such as tobacco taxes, to maximize the intervention’s impact (Pearson et al. 2017).

A simulation of four retailer density reduction strategies in Ohio predicted that reducing retailer-to-retailer proximity and capping the number of retailers are strategies that, on their own, would result in the greatest reduction in the number of retailers. This study predicted that retailer-to-retailer proximity policies would have the most impact in high-poverty neighborhoods and African American neighborhoods, whereas capping the number of retailers would have the most impact in high-poverty neighborhoods and rural neighborhoods (Craigmile et al. 2021).

As noted in Chapter 5, there is mixed evidence that retailer proximity to schools impacts some tobacco-related behaviors among youth, including smoking prevalence and cigarette purchasing and borrowing behavior (Leatherdale and Strath 2007; Henriksen et al. 2008; McCarthy et al. 2009). However, a combination of policies, such as those that reduce retailer-to-retailer proximity and cap the number of retailers, may affect the density of retailers near one’s home and have a greater impact on preventing and reducing tobacco use among youth (Abdel Magid et al. 2020). Given that most people, including those experiencing tobacco-related health disparities, begin using tobacco products before the age of 25, these two policies—especially in combination—warrant investigation in terms of whether they also help reduce tobacco-related health disparities.

In summary, place-based strategies show promise in reducing the ubiquity of tobacco retail stores and, thus, the availability of tobacco products and exposure to tobacco marketing. The ability of place-based strategies to reduce initiation and promote cessation may vary depending on the demographics of the communities in which they are implemented. Retailer-to-school proximity, retailerto-retailer proximity, and retailer cap laws could reduce retailer density in neighborhoods with greater proportions of lower SES, Black, or Hispanic people. Tobacco-free pharmacy policies may have a population-level benefit but not reduce disparities. Thus, it is important to consider adopting tobacco-free pharmacy policies in conjunction with strategies that are likely to reduce tobacco use. The existing literature suggests that retail strategies would be most effective if more than one were adopted and if they were implemented as part of a tobacco retailer licensing program (Combs et al. 2020; Kong and King 2021). Requiring retail licenses to sell tobacco, a strategy recommended by the National Academy of Medicine, (1) could help jurisdictions understand who is selling tobacco products; (2) could be used as a mechanism to reduce tobacco retailer density by limiting the number, location, or type of retailers; and (3) could be used to help enforce other tobacco retail policies (IOM 2007).

Most of the published studies discussed in this section model the hypothetical impacts of place-based policies. Additional studies that examine how these policies can address tobacco-related health disparities are warranted.

#### Product-Based Strategies

This section discusses product-focused strategies, including increasing prices for tobacco products through tax and non-tax mechanisms and prohibiting the sale of flavored products.

##### Tobacco Pricing Policies

Decades of robust research across regions and countries and among different population groups has consistently shown that significantly raising the price of cigarettes is the single most effective strategy to reduce cigarette smoking (NCI and WHO 2016; NCI 2017b). Specifically, higher cigarette prices discourage and prevent smoking initiation among youth and young adults, increase smoking cessation among adults who smoke, prevent people who formerly smoked from relapsing, and decrease cigarette consumption among those who continue to smoke (Chaloupka 1999; IOM 2007; IARC and WHO 2011; The Community Guide 2012; USDHHS 2014, 2020; NCI and WHO 2016; Dahne et al. 2020a).

Generally, studies have found that a 10% increase in purchase price reduces cigarette consumption among adults by 2–6% (4% on average) in higher income countries, and by about 2–8% (5% on average) in lower and middle-income countries (NCI and WHO 2016). Similarly, a review by the Community Preventive Services Task Force of 116 studies from higher income countries concluded that a 20% increase in the price of tobacco products “would reduce overall consumption of tobacco products by 10.4%, prevalence of adult tobacco use by 3.6%, and initiation of tobacco use by young people by 8.6%” (The Community Guide 2012, p. 2; NCI and WHO 2016).

Over the last few decades, research has also demonstrated that the impact of raising cigarette prices on reducing smoking can vary among certain population groups, defined by SES, age, gender, and race and ethnicity (IARC 2011; NCI and WHO 2016; NCI 2017b). Importantly, price increases particularly benefit young people by deterring youth tobacco initiation (Chapman 2000; Chaloupka et al. 2011; IARC 2011; USDHHS 2012; NCI 2017b).

In addition to the key findings that higher prices prevent youth smoking initiation, the potential differential impact of higher cigarette prices on reducing cigarette consumption, preventing relapse, and encouraging cessation among different population groups has important policy implications. For example, research generally shows that people with lower incomes who use tobacco products are more responsive to price increases than people of higher incomes who use tobacco products, and that young people are more responsive to price increases than adults; people with substance use disorders or other behavioral health conditions also may be responsive to price increases (Ong et al. 2010; IARC 2011; Hill et al. 2014; NCI and WHO 2016; NCI 2017b; Smith et al. 2020). Raising tobacco prices may have the added benefit of further reducing tobacco use among these price-sensitive population groups beyond the overall reduction in tobacco use realized by the general population, which would, in turn, reduce tobacco-related health disparities (NCI and WHO 2016; NCI 2017b). This strategy may be especially helpful considering that cheaper tobacco products are marketed to young people and to population groups that experience tobacco-related health disparities, as discussed in Chapter 5 (Henriksen et al. 2020; Raskind et al. 2022).

Comprehensive and systematic reviews of studies examining the overall impact of tobacco prices on tobacco use have been conducted elsewhere (IARC 2011; USDHHS 2014; NCI and WHO 2016). This section (1) highlights research that examined the differential impact of tobacco prices among population groups; (2) synthesizes relevant studies that have been published since the previous comprehensive reviews; and (3) discusses research gaps in understanding how tobacco pricing policies can be used effectively to reduce tobacco-related health disparities. The evidence is organized around the policy tools that affect tobacco retail prices. Under each policy tool, and when evidence is available, studies are summarized for population groups that experience tobacco-related health disparities.

Tobacco product prices and demand. Several policies could affect retail prices for tobacco products, with the most widely implemented policy being the levying of tobacco-specific excise taxes (discussed in more detail later in this section). In addition to tobacco-specific excise taxes, minimum price laws, which require tobacco product prices (at the manufacturer, wholesale, or retail level) to be above a predetermined floor, could influence the retail prices of tobacco products. Similarly, minimum markup laws, which require a minimum markup above manufacturer or wholesale prices, could influence retail prices. In addition, policies that prohibit price-reducing strategies, such as prohibiting coupons and discounts, direct promotion to retailers, and free samples could influence how much consumers pay for tobacco products (Golden et al. 2016).

Because multiple policy approaches influence tobacco use behaviors through their impact on tobacco retail prices, this section begins by summarizing the evidence on the impact of cigarette retail prices on smoking. One of the most widely used measures to assess how responsive cigarette consumption is to changes in cigarette price is price elasticity of demand, which is the degree of responsiveness of quantity demanded to a change in price. For example, a price elasticity of −0.4 means that a 10% increase in cigarette prices will result in a 4% decrease in the quantity demanded.

Demand for little cigars and cigarillos is more elastic (i.e., sensitive to price changes) compared with other cigars, and the price elasticity for smokeless tobacco varies depending on the type of product (Huang et al. 2018). Studies on price elasticity for smokeless tobacco may have mixed results because price increases for some products (e.g., dry snuff and chewing tobacco) may reduce demand more than price increases for other products (e.g., moist snuff and snus), and studies tend to combine many different smokeless tobacco products into one broad category (Huang et al. 2018). Data from the United States on price elasticity for tobacco products other than cigarettes, broken down by population group, are limited.

Differential impact of cigarette prices by SES. People of lower SES are especially sensitive to significant tax and price increases and consistently reduce their consumption of cigarettes in response to price increases (NCI 2017b). In one of the earliest studies to examine the impact of cigarette price on smoking, Chaloupka (1991), analyzing data compiled from the National Health and Nutrition Examination Survey, found that people with fewer years of formal schooling were more responsive to changes in cigarette prices than were people with more years of formal education. In fact, people with more education did not change their cigarette consumption in response to changes in cigarette prices.

Several studies assessing various prevalence surveys in the United States provide additional evidence that corroborates the finding that price responsiveness and income levels are inversely related, indicating that people with lower incomes were more price responsive than their higher income counterparts in the United States (CDC 1998; Hersch 2000; Farrelly et al. 2001; Gruber and Koszegi 2004; Levy et al. 2006; Colman and Remler 2008; DeCicca and McLeod 2008; Farrelly and Engelen 2008). A systematic review by Brown and colleagues (2014) found that 27 studies published from 1995 through 2013 concluded that cigarette price or tax increases in Australia, Canada, Europe, and the United States were associated with larger reductions in tobacco use and prevalence among lower SES population groups as compared with higher SES population groups. Fourteen of the 27 studies demonstrated a positive equity impact (defined in the study as reduced socioeconomic inequalities in smoking among adults). Of the remainder, six were neutral, one was mixed, two were unclear, and four were negative. Of the seven categories of interventions reviewed, price or tax increases had the most consistent positive equity impact with respect to this population. The authors noted that, because people of lower SES are more price sensitive, some studies may capture short-term reductions in use and not necessarily sustained quitting (Brown et al. 2014).

This literature has important policy implications. Specifically, although people of lower SES are more likely to smoke, use a larger share of their income to purchase tobacco products, and, as a group, bear a disproportionate share of the tobacco health burden, they are also more likely to reduce their cigarette consumption in response to an increase in cigarette price (IARC 2011). An increase in cigarette price might result in a greater benefit (in terms of reduced tobacco use) among people who smoke with lower SES than people who smoke with higher SES due to reduced consumption or increased quitting (IARC 2011). This could ultimately lead to reductions in tobacco-related health disparities by SES. However, if tax increases are too modest, they may result in reduced consumption but not cessation (Colman and Remler 2008; Verguet et al. 2021).

The benefit of increasing cigarette prices would be even larger if the increased tax revenue were earmarked for tobacco control programs and other health programs that serve lower SES population groups, particularly for sustained cessation interventions to reach people who may not quit in response to the price increase or people who are at risk of relapse (Colman and Remler 2008; Blakely and Gartner 2019; Fuchs et al. 2019; WHO n.d.).

Despite these findings, lower priced alternatives to cigarettes can undermine the impact of cigarette price increases. For example, as documented in the 2014 Surgeon General’s report, when the federal tax on cigarettes, cigarette-like small cigars, and “roll your own” tobacco was increased in 2009, the industry changed some of its products and product packaging to avoid the tax (USDHHS 2014). Specifically, tobacco companies slightly increased the weight of little cigars so that they shifted to the cigar category, which is more favorable for tax purposes. This allowed for the introduction of a new “filtered cigar” product with a lower retail price than little cigars and cigarettes (USDHHS 2014). This practice is believed to partially account for increased use of cigars, which are disproportionately used by certain groups, such as Black high school students (see Chapter 2) (NCI 2017b). Parity in taxation across products could help to prevent similar situations.

Differential impact of cigarette prices by race and ethnicity. The studies highlighted in this section specifically examined the differential impact of cigarette price by race and ethnicity. As discussed in NCI Tobacco Control Monograph 22, research has generally found that Hispanic and Black adolescents and adults are more responsive to changes in cigarette prices than their White counterparts, in terms of smoking prevalence, consumption of cigarettes, and smoking initiation (NCI 2017b). For instance, a study conducted by Chaloupka and Pacula (1999) was one of the first to examine racial differences in the impact of cigarette prices on the prevalence of smoking among adolescents. Using data from the 1992, 1993, and 1994 Monitoring the Future (MTF) Study and controlling for SES, the authors found that Black adolescents who smoked were more responsive to price changes than were White adolescents who smoked, with the estimated prevalence price elasticity of demand −1.11 for Black adolescents, compared with −0.64 for White adolescents.

Later, using data from the MTF Study and the Youth Risk Behavior Surveillance System, Gruber and Zinman (2001) found that White 12th graders were relatively less responsive to changes in cigarette prices compared with 12th graders who were Black or characterized by the study as “non-White.” Black and “non-White” 12th graders were extremely responsive to these changes, although similar findings were not reached when they analyzed price responsiveness among Black and White teen mothers. Using data from the 1991–2010 MTF Study surveys, another study (Tauras et al. 2013) found that Black and Hispanic youth had the strongest response to cigarette price changes among all racial and ethnic population groups, with their price elasticities estimated to be −0.72 and −0.44, respectively. Farrelly and colleagues (2001) found that NHIS data from 1976 to 1993 showed that Black adults and Hispanic adults were more than two and six times as responsive to cigarette prices, respectively, compared with White adults.

In contrast, a study (Yao et al. 2018) that evaluated the impact of cigarette prices on adult smoking participation (use vs. no use) and smoking intensity among four U.S. racial and ethnic groups—White, African American, Asian, and Hispanic—using the 2006–2011 TUS-CPS found that African American and Hispanic adults were less sensitive to cigarette price changes than White adults (total price elasticity of cigarette demand was −0.27 and −0.15, respectively, vs. −0.48, meaning that a 20% increase in cigarette price would be expected to reduce the quantity of cigarettes demanded by 5.4% among African American adults and by 3.0% among Hispanic adults compared to 9.6% among White adults). Asian adults were more price-sensitive than White adults relative to smoking participation (−0.42 vs −0.26) but they were not sensitive to price with respect to smoking intensity. Given the differences in price sensitivity across the population groups, the authors suggested that tobacco tax increases should be implemented with tailored, non-price-related tobacco control strategies to ensure that tobacco control policy interventions reach all population groups. Similarly, Parks and colleagues (2021, 2022) conducted two studies using longitudinal data from the MTF Study (2001–2017 and 2000–2014 data) to examine the impact of cigarette prices on smoking behaviors among young adults from the age of 18 to 19–20 and 21–22 years of age. The studies found that changes in cigarette pack price may not affect existing disparities in cigarette use among young adults. The authors discussed evidence showing that tobacco taxes can reduce tobacco use in the general population, including among adolescents (Fleischer et al. 2021), and that taxes may also reduce disparities among older adults, but the authors concluded that their findings suggest that other policies, such as menthol bans, may have higher potential than tax policies to reduce racial and ethnic disparities in tobacco use among young adults.

In conclusion, most people initiate tobacco use before the age of 25. Youth are especially price-sensitive, and cigarette price increases could help address health disparities among people at the age when they are most likely to begin smoking. There is evidence that Black and Hispanic youth are more sensitive to price increases for cigarettes than are youth from other racial and ethnic groups, such as White youth. However, the differential impact of cigarette price increases by race and ethnicity may have changed over time (Fleischer et al. 2021). The evidence is mixed regarding the impact of cigarette price increases on reducing racial and ethnic disparities in tobacco use among adults.

Cigarette excise taxes. Tobacco excise taxation policies represent one of the most widely used and direct policy strategies to increase the retail prices of cigarettes. Studies that examined who bore the economic burden of cigarette taxes have generally assessed whether cigarette taxes were overshifted (the retail price increase was larger than the tax increase) or undershifted (the retail price increase was smaller than the tax increase) (see Chapter 5 for additional details on undershifting and overshifting). Analyzing consumer-reported prices from the 2003 and 2006–2007 TUS-CPS, DeCicca and colleagues (2015) and Pesko and colleagues (2013) documented a pass-through rate of approximately 1, indicating that consumers bear approximately 100% of the burden of taxes.

The degree of pass-through could be reduced by price-minimizing behaviors among people who smoke. These behaviors can include purchasing cartons or buying in bulk, using coupons, buying cigarettes from retailers on tribal reservations (which may be less expensive), and purchasing generic brands (Xu et al. 2014). A cigarette tax increase may have the greatest impact on reducing tobacco use when the tax increase is large and combined with comprehensive cessation support. A 2019 study of data from the Minnesota Adult Tobacco Survey found that following a cigarette tax increase, the perceived tax increase effect and low nicotine dependence were associated with making a quit attempt in adjusted models (Boyle et al. 2019). Predictors of successful quit attempts were college education, use of cessation support, and reporting that the tax increase had helped to maintain a quit.

An evaluation of a 2002 strategy in New York City that increased cigarette excise taxes, extended the scope of its smokefree law, increased cessation services, and expanded public education efforts showed declines in smoking prevalence across all population groups (Frieden et al. 2005). It attributed 33% to 54% of the decline in smoking prevalence—which was greatest among young adults 18–24 years of age and was greater among Black, Hispanic, and Asian adults than among White adults—to the excise tax increase. The study attributed 13–21% of the reduced smoking prevalence to the extension of the smokefree law, and 8% to the increased cessation services. The authors suggested that the remaining decline may have been caused by the synergistic effects of the four interventions.

More evidence is needed to fully document the extent to which sociodemographic population groups, other than people of lower SES and youth, respond differentially to increases in cigarette excise taxes. This evidence is critical to fully understand the impact of cigarette excise tax increases on tobacco-related health disparities and helpful for understanding the broader public health and economic benefits that individual jurisdictions can expect to experience (Chaloupka et al. 2012).

Non-tax tobacco pricing policies. Tobacco companies use a variety of strategies to mitigate the impact of higher tobacco taxes (see Chapter 5). For example, they may reduce tax pass-through to minimize the price increases on lower priced brands, offer price discounts to retailers, and give coupons to consumers (Ross et al. 2017; Ribisl et al. 2022). Of the $7.62 billion that cigarette companies spent on advertising and promotion in 2019, approximately 75% ($5.7 billion) was paid to retailers and wholesalers to reduce cigarette prices (Federal Trade Commission 2021; CDC n.d.k). As such, tobacco control policy efforts that complement tobacco excise taxes, such as minimum price laws and prohibitions on price promotions, are also warranted (Golden et al. 2016; Ribisl et al. 2022).

There are two types of minimum price laws: minimum markup and minimum retail price. Minimum markup policies require tobacco to be sold at a minimum markup (e.g., $1–$10) above the manufacturer and/or wholesale price. Tobacco companies can undermine the effects of minimum markup policies by offering trade discounts to manufacturers and retailers that lower the base price, so the markup is applied to the new, discounted base price (Tobacco Control Legal Consortium 2011). A minimum retail price policy requires tobacco product prices at the manufacturer, wholesale, and/or retail level to be above a predetermined minimum. This section focuses on minimum retail price policies, which set a pricing floor for the actual purchase price and better protect the purchase price from tobacco industry manipulation.

Findings from one modeling study (Doogan et al. 2018) suggest that the impact of a federal minimum price requirement for cigarettes could range from a minimal effect at the $4 level, to a reduction of 5.7 billion packs of cigarettes sold per year and 10 million fewer people who smoke at the $10 level. Another modeling study (Marynak et al. 2016) complemented these findings and predicted that the introduction of a $10 per-pack minimum retail price could significantly reduce the prevalence of smoking, particularly when accompanied by legislation to ban price promotions and discounts. The projected effects were especially large among adults 18–25 years of age, with this intervention associated with an estimated 12% decrease in the prevalence of smoking among members of this age group.

Golden and colleagues (2016) note that strong minimum retail price laws could eliminate discount brands from the market and increase the average prices for middle-priced brands. Because people with lower incomes who smoke are more likely to buy discount brands, the removal of these products from the market could reduce use among people with lower incomes. Mills and colleagues (2020) found that New York was the only U.S. state that reduced disparities in smoking between lower and higher income population groups between 2011 and 2017. Although the authors did not evaluate the impact of specific policies, they noted that further research was warranted given that during this timeframe the state increased its cigarette tax and New York City (where nearly two-thirds of the state’s residents live) implemented a minimum price policy.

In one study, Ribisl and colleagues (2022) noted that the evaluation data analyzing the effects of minimum retail price policies were of somewhat limited utility because the minimum prices in the two jurisdictions that were evaluated were lower than the average price before the policies were adopted. Many countries have implemented minimum excise tax laws to ensure that a minimum baseline tax is paid on each product, regardless of its wholesale price; this may be a potential alternative in jurisdictions with effective excise tax systems that wish to direct all revenue increases to the government rather than allowing the industry to possibly obtain increased revenue as the result of a minimum price law (Ribisl et al. 2022). Although minimum price laws or minimum excise tax laws would be expected to help reduce tobacco use among people with lower incomes and other price-sensitive consumers, more research on these strategies and their impact on the wider array of population groups experiencing tobacco-related disparities is necessary.

Prohibiting price promotions (e.g., discounts, multipack offers, redemption of coupons) is another non-tax tobacco pricing strategy intended to maximize the impact of tobacco excise taxes and minimum price laws. Studies have documented tobacco price-related discounts offered to or used by people experiencing disparities (Moran et al. 2019). For example, Xu and colleagues (2016) found that data from the National Adult Tobacco Survey from 2009 to 2010 showed that the use of discounts was most common among people who smoked premium cigarette brands and that, within that group, discount use was most common among people under 65 years of age, non-Hispanic Native Hawaiian and Pacific Islander people, and people with low incomes.

Cornelius and colleagues (2014) analyzed data from the ITC Project’s cohort of U.S. adults who smoke and were recruited and followed from 2002 through 2011. That study found an increase in people using discounted cigarette brands after the federal cigarette excise tax was increased in 2009, including older people and people with lower incomes. A study examining 2013–2014 data from the U.S. PATH Study showed that adults with lower incomes were more likely than adults with higher incomes to receive coupons for tobacco products, and that receipt of the coupons through direct mail or email increased the chances that someone who did not smoke would start smoking and decreased the odds that someone who currently smoked would successfully quit (National Institutes of Health [NIH] 2017; Choi et al. 2018). Findings from a study by El-Toukhy and colleagues (2018) that examined national bans on tobacco price promotions, including tobacco product coupons, using data from the 2008 to 2011 ITC Project indicated that national bans could reduce exposure to tobacco price promotions and thereby eliminate their association with smoking behaviors.

Strategies that have been studied less but may warrant further investigation include minimum pack size requirements and fee-based policies. Minimum pack size laws require a minimum number of units per pack and aim to reduce the availability of inexpensive cigarillos and little cigars. For example, although cigarettes are required to be sold in packs of 20 in the United States, similar minimum pack size requirements are not required for other tobacco products. This allows for smaller unit sales and, therefore, lower prices. Smaller pack sizes may affect younger adults who are experimenting with cigar products and styles (Ganz et al. 2021). Given disparities in cigar use among young people (at ages when most tobacco use initiation occurs) (Chen-Sankey et al. 2021; Gentzke et al. 2022) as well as increased cigar use between 2013–2014 and 2018–2019 among Black adults, Hispanic adults, and adults with a high school diploma or less (NIH and FDA 2021), this type of strategy could hold promise for reducing disparities in cigar use.

Fee-based policies include tobacco retail license fees to manage retailer licensing programs or fees directly applied to tobacco products to offset costs incurred by the government for activities such as mitigating cigarette litter and other tobacco waste (Golden et al. 2016). Because the costs associated with these fees may be passed on to the consumer, it is possible that they could affect consumption. However, because licensing fees usually cannot exceed the costs of implementing the services to which they are attached, the resulting increase in tobacco product prices may be too incremental to have an impact on consumption among the general population or among people experiencing disparities.

Taxation and other pricing policies for newer tobacco products. Research on the impact of price strategies, including taxation and prohibitions on price-reducing promotions, pertaining to e-cigarettes and other newer tobacco products is relatively limited compared with the substantial amount of research on the impact of such policies on the use of cigarettes. Most existing studies of this topic have examined the extent to which e-cigarette use may decrease in response to e-cigarette tax or pricing policies or whether other products may be used as substitutes for e-cigarettes (or vice versa) when products are not taxed at parity (Huang et al. 2018; Pesko et al. 2020; Yao et al. 2020; Wang et al. 2021; Cotti et al. 2022; Diaz et al. 2023). Other research has documented the variation in e-cigarette taxation strategies and made preliminary recommendations, based on states’ experiences, on effective ways to tax e-cigarettes and other newer tobacco products, such as heated tobacco products (Chaloupka and Tauras 2020; Shang et al. 2021; Dauchy and Shang 2022).

Studies that explore the potential differential impact of pricing policies on the use of noncigarette tobacco products among various population groups and the potential impact to reduce tobacco-related disparities are warranted.

##### Prohibiting the Sale of Flavored Tobacco Products

In 2014, the Surgeon General’s report, The Health Consequences of Smoking—50 Years of Progress concluded that a promising endgame strategy for eliminating smoking in the United States was to impose greater restrictions on sales of products, including banning entire categories of tobacco products (USDHHS 2014). As discussed earlier in this chapter, the Tobacco Control Act expressly preserves state, territorial, tribal, and local authority to adopt and enforce requirements related to the sale and distribution of tobacco products (Family Smoking Prevention and Tobacco Control Act 2009). States, territories, tribes, and localities have enacted a variety of laws that prohibit the sale of tobacco products, such as those that prohibit online sales, the sale of products that have not received premarket authorization from FDA, and the sale of tobacco products altogether (described more fully in Chapter 8) (City and County of San Francisco 2019; Public Health Law Center 2019a; Kong and King 2021).

In the United States, the sales restriction laws most frequently adopted in recent years are those that prohibit the sale of flavored tobacco products (Rogers et al. 2022b; Truth Initiative n.d.). As of February 2024, nearly 200 of the more than 375 local and tribal laws restricting the sale of flavored tobacco products include restrictions on the sale of menthol cigarettes, the only type of flavored cigarette that still can be sold under federal law (Truth Initiative 2023; Campaign for Tobacco-Free Kids 2024b).

In June 2020, Massachusetts became the first state to implement a restriction on the sale of flavored tobacco products that applies to menthol cigarettes (Campaign for Tobacco-Free Kids 2024b). A similar law was passed in California in August 2020 but was put on hold pending the results of a referendum vote in November 2022 (Campaign for Tobacco-Free Kids 2022). The voters approved California’s law, which went into effect in December 2022 (Angst et al. 2022; Public Health Law Center 2022a; Campaign for Tobacco-Free Kids 2024a). Courts have found that the Family Smoking Prevention and Tobacco Control Act does not preempt local governments from restricting the sale of flavored tobacco products (National Association of Tobacco Outlets, Inc. v. City of Providence, R.I. 2013; Independents Gas & Service Stations Associations Inc. v. City of Chicago 2015).

As described earlier in this chapter (see “Elimination of Flavors in Tobacco Products” section) and summarized in Tables 7.3 and 7.4, there is strong evidence regarding the role of flavored tobacco products in creating and sustaining tobacco use and the efficacy of policies that prohibit the sale of flavored products.

Further, sales restrictions on flavored products in the United States and Canada have been shown to reduce (1) sales of tobacco products, (2) the odds of youth trying flavored tobacco products, (3) the odds of youth ever using tobacco products, and (4) youth current use of tobacco products, particularly when the restrictions apply to all flavors in all tobacco products (Farley and Johns 2017; Rogers et al. 2017, 2020; Kingsley et al. 2019; Pearlman et al. 2019; Chaiton et al. 2020a; Gammon et al. 2021; Asare et al. 2022; Olson et al. 2022a,b; Satchell et al. 2022; FDA 2022c). Surveys and experimental studies, as well as evaluation studies from Canada and the Netherlands, suggest that prohibiting the sale of menthol cigarettes will lead to (1) declines in menthol cigarette sales and in smoking, (2) increased quit attempts among people who smoke menthol versus nonmenthol cigarettes, and (3) increased likelihood of successful quitting. Further, the effect may be greater among people from minoritized racial and ethnic groups than it is among White people, among women than it is among men, among young adults than it is among older adults, and among other population groups that have disproportionately higher use of menthol cigarettes (Hymowitz et al. 1995; WHO 2016a; Chaiton et al. 2018, 2020c, 2021b; Rose et al. 2019; Bold et al. 2020; Cadham et al. 2020; Chung-Hall et al. 2022; Kyriakos et al. 2022).

A study measuring the potential equity impact of a range of state and local restrictions on flavored sales in the United States found that, as of December 31, 2018, existing policies reached certain population groups experiencing health disparities, such as people of lower SES, young adults, women, and partnered same-sex households (Rose et al. 2020a). The study also found that although the policies generally reached African American people, the proportion of African American people protected by a strong policy (i.e., applied to menthol cigarettes and also applied throughout the entire jurisdiction, rather than only near schools or other limited geographic areas) was smaller than the proportion of African American people in the national population. In addition, the study found a notable lack of flavor policies reaching American Indian and Alaskan Native people and Native Hawaiian and Pacific Islander people, population groups that have some of the greatest tobacco use disparities (Rose et al. 2020a).

Table 7.4 Studies of the impact of eliminating or prohibiting the sale of flavors in tobacco products on sales of tobacco products

Study | Design, population, and location | Primary outcome(s) | Results
Rogers et al. (2017) | - Pre-post design with control group; - Used retail scanner data from The Nielsen Company from January 2010 to January 2014 for New York City, a proximal comparison area surrounding New York City and the United States to examine the effects of the city’s policy (passed in October 2009 and implemented in July 2010) of restricting the sales of flavored, non-cigarette tobacco products; - Used regression models to assess trends in sales of flavored cigars, smokeless tobacco, loose tobacco, and total cigars | - Assessed the effects on retail sales of New York City’s policy to restrict sales of flavored non-cigarette tobacco products; - Assessed possible cross-border purchasing and product substitution by consumers | - Unit sales declined significantly (all p <0.01) after policy implementation:; – All flavored tobacco products combined: −27.1%; – Flavored cigars: −22.3%; – Flavored smokeless tobacco: −97.6%; – Flavored roll-your-own tobacco: −42.5%; - For total cigar sales, implementation was associated with; – An immediate and significant decrease of 11.6% in New York City (p <0.05); – A non-significant decrease of 6.4% in the control area; – A non-significant increase of 2.1% nationally; - Average pre-to-post sales of all cigars:; – Decreased 7.4% in New York City (p <0.01); – Increased 9.8% in the control area (p <0.01); – Increased 12.0% nationally (p <0.01)
Chaiton et al. (2019) | - Pre-post design; - Repeated data from 2001 to 2016 were reported by manufacturers to Health Canada; - Interrupted time series analysis was used to examine the association between nationwide Canadian regulations passed in 2009 banning flavor additives (except menthol) in cigarettes and all cigars under 1.4 g (or any cigar with a filter or non-spiral wrap) and changes in cigar sales | - Estimated changes in sales of cigars with and without flavors; - Assessed changes in flavor types over time | - Sales of flavored cigars decreased significantly by 59.2 million units (95% CI, −86.0 to −32.4, p <0.001) in the quarter immediately following policy enactment; - Overall sales of cigars decreased 49.6 million units (95% CI, −73.5–25.8, p <0.001) in the quarter immediately following policy enactment
Chaiton et al. (2020b) | - Pre-post design with control group; - Analyzed before-and-after data from the ban on menthol tobacco products in Ontario, Canada, in May 2015; the province of British Columbia was the comparison; - Used interrupted time series analysis to examine wholesale data from October 2012 to September 2017 from manufacturers in Health Canada | - Assessed the effects of a provincial ban on menthol on wholesale cigarette sales in Ontario; - Estimated changes in sales of cigarettes with and without menthol | - In the month immediately after policy implementation in Ontario, sales of menthol cigarettes declined 55 million units (95% CI, −78.5 to −31.5; p <0.01) and overall sales of cigarettes declined 127.8 million units (95% CI, −208.2 to −47.4; p <0.01), both relative to the control; - The significant decline in the overall sales of cigarette units in Ontario after policy implementation was followed by a significant increase in the sale of nonmenthol cigarettes: 23.8 million units per month (95% CI, 10.2–37.4; p <0.001) relative to the control during the post-policy period
Rogers et al. (2020) | - Pre-post design with comparison group; - Used weekly retail scanner sales data from The Nielson Company from January 2012 to December 2016 to evaluate the effects of enforcing restrictions on retail sales of all non-cigarette flavored tobacco products (excluding menthol) in Providence, Rhode Island, over time and compared with the rest of the state; - Used regression models to assess changes in sales in Providence and in the rest of the state before and after the restriction policy was implemented | - Assessed the impact of the policy on sales of cigars in Providence and in the rest of the state of Rhode Island | - Average weekly sales of units of flavored cigars decreased by 51% (p <0.01) in Providence but increased by 10% (p <0.01) in the rest of the state; - The decline in flavored cigar sales in Providence is attributed to a 93% reduction (p <0.01) in sales of cigars labeled with explicit names of flavors.; - Average weekly sales of units of cigars labeled with concept flavor names increased by 74% in Providence and by 119% in the rest of the state (both p <0.01); - Overall sales of cigars decreased 31% (p <0.01) in Providence
Chaiton et al. (2021b) | - Pre-post design with no control or comparison; - Economic evaluation used data from wholesale cigarette sales reported by manufacturers to Health Canada to compare sales of cigarettes before and after the implementation of provincial bans of menthol cigarettes starting in May 2015 and of a nationwide ban of menthol cigarettes starting in October 2017; - Conducted interrupted time series regression analyses | - Assessed overall changes in cigarette sales between 2010 and 2018 in association with the implementation of menthol cigarette bans in Canada | - After the bans (province specific from May 2015 to October 2017), sales of menthol cigarettes decreased to 0 in all provinces; the overall percentage change in cigarette sales compared to the same month in the previous year was −4.6% (95% CI, −8.2% to −1.0%; p = 0.02); - Wholesale cigarette sales decreased in all 10 Canadian provinces that were studied after the ban on menthol cigarettes; the decrease was statistically significant (p <0.05) in three provinces (Alberta, New Brunswick, and Saskatchewan)
Asare et al. (2022) | - Pre-post design with comparison group; - Used retail scanner data, from The Nielsen Company, of sales volumes of menthol and non-flavored cigarette brands sold by U.S.-based retailers; - Examined, per 1,000 people, state-level sales of packs of menthol, non-flavored, and all cigarettes from January 2017 to July 2021, based on state-level annual population data obtained from the U.S. Census Bureau; - Controlled pre-post design with difference-in differences model to examine temporal changes in sales of cigarettes in Massachusetts before (January 2017–May 2020) and after (June 2020–July 2021) a comprehensive ban on menthol-flavored tobacco products and in states without a flavor ban during this period; - Analyzed 1,652 observations of data from 4-week sales of cigarettes: 59 observations from Massachusetts and 1,593 observations from comparison states | - Examined whether cigarette sales changed after Massachusetts banned menthol-flavored tobacco products compared with sales in other U.S. states without a flavor ban | - After the comprehensive ban on flavored tobacco products (including menthol) in Massachusetts, the unadjusted 4-week sales of packs of cigarettes per 1,000 people decreased in Massachusetts for menthol (from 404.93 packs to 32.24), non-flavored (from 916.37 packs to 856.79), and all (from 1,321.32 packs to 887.69) cigarettes; - The unadjusted 4-week sales of packs of cigarettes per 1,000 people also decreased during this period in comparison states.; - After the flavor ban and compared with control states, the adjusted 4-week sales of cigarettes in Massachusetts decreased by 372.27 (95% CI, −428.90 to −315.64, p <0.001) packs per 1,000 people for menthol cigarettes but increased by 120.25 (95% CI, 72.61–167.88; p <0.001) packs per 1,000 people for non-flavored cigarettes; - Overall, the adjusted 4-week sales of all cigarettes (menthol and non-flavored) decreased by 282.65 (95% CI, −356.07 to −209.23; p <0.001) packs per 1,000 people in Massachusetts compared with control states.
Kingsley et al. (2022) | - Pre-post design with comparison group; - Massachusetts used rigorous enforcement infrastructure to communicate with and provide educational visits to retailers before and after the implementation of a policy to restrict the sales of menthol and other flavored tobacco products; - Used retail scanner data from The Nielsen Company, which provided timely surveillance data, to monitor compliance with and evaluate the impact of the policy; - Compared data from 3 years before the policy was implemented to 1 year after it began (June 2017–June 2021) in five state-specific markets in Massachusetts and four neighboring control states (New Hampshire, New York, Rhode Island, and Vermont); - Aggregated unit sales of four categories of tobacco (cigarettes, cigars/cigarillos, smokeless tobacco, and vape products) were stratified by flavor category (menthol, other flavor, and unflavored) | - Evaluated the impact of statewide law in Massachusetts that restricted in June 2020 sales of menthol and other flavored tobacco products | - One year after implementation of the policy, overall tobacco sales in Massachusetts decreased 25.4% (from 33,917,494 to 25,315,189 units) compared with the previous year; - Compared with the previous year, sales of:; – Unflavored tobacco products increased by 10.3% (from 22,609,326 to 24,947,827 units); – Menthol products decreased by 96.9% (from 10,355,518 to 317,863 units); – Other flavored tobacco products decreased by 94.8% (from 952,650 to 49,499 units); - One year after implementation of the policy, total sales of tobacco products in neighboring control states decreased by 1.8% (from 106,863,560 to 104,937,096 units) compared with the previous year
Olson et al. (2022b) | - Pre-post design with comparison group; - Used NielsenIQ retail scanner data from 2015 to 2019 and single-group, interrupted time series models to compare tobacco sales before and after Minneapolis and St. Paul, Minnesota, expanded existing local sales restrictions on flavored tobacco products to include menthol-, mint-, and wintergreen-flavored products, with exemptions for certain types of stores; - Comparison NielsenIQ retail scanner data from 2015 to 2019 for the rest of the state of Minnesota and the total United States was also assessed | - Analyzed unit sales of tobacco products by product category and by flavor for the communities with sales restrictions in Minneapolis and St. Paul and compared those units with the rest of state and with the United States | - Unit sales of menthol cigarettes and menthol smokeless tobacco products decreased in both cities; smaller decreases occurred in comparison areas; - Sales of flavored cigars decreased after implementation of the initial flavor policy and decreased further after that policy was expanded in 2019; - Sales of menthol-flavored e-cigarettes increased in both cities and sales of flavored e-cigarettes increased in St. Paul; these increases may be associated with legal sales by exempt retailers or illicit sales by noncompliant retailers
Satchell et al. (2022) | - Pre-post design with comparison group; - Used NielsenIQ retail scanner data and difference-in-differences models to compare (a) comprehensive restrictions on flavored tobacco products in Massachusetts in June 2020 and (b) partial restrictions on flavored tobacco products (prohibiting the sale and distribution of flavored e-cigarettes but excluded menthol cigarettes and other flavored combustible tobacco products) in New Jersey in April 2020, with two control states: Virginia and Pennsylvania | - Evaluated the impacts of comprehensive tobacco sales restrictions in Massachusetts and of partial tobacco sales restrictions in New Jersey | - In Massachusetts, sales decreased significantly for all flavored tobacco products, including; – Fruit (−99.83%, p <0.01), menthol (−98.33%, p <0.01), tobacco-flavored (−81.18%, p <0.05), and all other flavored (−99.28%, p <0.01) e-cigarettes;; – Fruit (−95.45%, p <0.05) and all other flavored cigars (−99.92%, p <0.01); and; – Menthol cigarettes (−95.36%, p <0.01); - In New Jersey, sales decreased significantly per capita for menthol-flavored e-cigarettes (−83.80%, p <0.05), but sales of all other-flavored cigars, including menthol-flavored cigars, increased significantly per capita (380.66%, p <0.01)

Note. CI = confidence interval.

One study outlined a proposed classification system to examine state and local sales restrictions on flavored tobacco products, guided by relevant studies, legal resources, and experts on flavored tobacco products (Donovan et al. 2021). The authors recommended that policies prohibit the sale of menthol cigarettes and all other flavored tobacco products (e.g., cigars, e-cigarettes, smokeless, hookah) and avoid exemptions for certain types of retailers to prevent youth initiation and reduce tobacco-related disparities, to reduce industry exploitation of policy gaps, and aid enforcement (Donovan et al. 2021).

From a public health perspective, territories, tribes, states, and localities would benefit from continuing to implement comprehensive policies in this arena, despite FDA’s stated intent to move forward with rulemaking to eliminate certain flavored tobacco products (cigarettes with menthol as a characterizing flavor and cigars with any characterizing flavors), given the breadth of flavored products on the market, the length of the federal rulemaking process, and potential litigation delays following publication of a final rule (Public Health Law Center 2021a).

Sustained implementation of evidence-based policies at the federal, territorial, tribal, state, and local levels is needed to accelerate the decline of tobacco use in the United States, including among people experiencing tobacco-related health disparities (USDHHS 2014). As discussed earlier in this chapter, there is strong evidence that prohibiting the sale of flavored tobacco products would reduce tobacco-related health disparities. Researchers have proposed a framework for engaging communities and centering equity through each stage of the policy process (Rose et al. 2022b).

The impact of any population-level tobacco control policy will be maximized if access to evidence-based cessation services is ensured (USDHHS 2020). Because people who smoke menthol cigarettes can face more difficulties quitting smoking, it is particularly important to promote, and have accessible, evidence-based cessation treatments when implementing policies prohibiting the sale of flavored tobacco products. Some researchers have suggested that menthol-flavored e-cigarettes may help people who smoke menthol cigarettes transition away from cigarette smoking (Webb Hooper and Smiley 2018; Mok et al. 2023). However, this has not been clinically evaluated. Through the premarket review process, FDA assesses whether allowing the marketing of the menthol-flavored e-cigarette for which an application has been submitted is appropriate for the protection of public health, considering the risks and benefits to the population as a whole and taking into account the likely impact on initiation and cessation.

Cessation treatments, and their promotion, are discussed in further detail elsewhere in this chapter. In addition, it is important to continue to evaluate territorial, tribal, state, and local policies to develop a better understanding of evolving promising practices both with respect to communicating the effectiveness of these policies to community members (Wackowski et al. 2018) and decision makers and with respect to implementing and enforcing the policies in ways that maximize their effectiveness. It also is essential to continue updating and sustaining surveillance systems to monitor tobacco-related health disparities and to better understand which complementary interventions (such as retailer reduction policies) (Combs et al. 2020) may be needed to further reach certain population groups.

#### Summary and Recommendations

This section described the evidence base regarding the impact of place-based and product-focused retail policy strategies on tobacco use patterns at the population level and among specific groups. Place-based interventions that reduce the number of tobacco retailers increase the time and resources needed to obtain tobacco products and likely have the added benefit of reducing exposure to tobacco advertising and product displays. As such, these interventions can contribute to reducing tobacco use initiation and cigarette cravings and to supporting cessation. Product-focused interventions reduce initiation and consumption, promote quitting, and reduce smoking-induced deprivation among those who quit smoking. Both types of policies can influence social norms around tobacco, further discouraging initiation and improving cessation outcomes.

Retail policies may be more effective and equitable if more than one policy were to be applied in concert with one another and if they were implemented as part of a tobacco retailer licensing program. They may also have a greater impact if accompanied by retailer education to help overcome industry influence (Blackman et al. 2019). Specifically, the evidence suggests that tobacco-free pharmacy policies may have a population-level benefit but not reduce tobacco-related disparities as there are lower odds of pharmacies being located in neighborhoods with high proportions of lower income people or minoritized racial and ethnic groups compared with higher income groups or predominately White neighborhoods. However, these policies could have more impact when combined with other retail strategies, especially given their potential to change social norms regarding tobacco use. The evidence suggests that reducing the number of retailers near schools would help reduce the density of retailers in neighborhoods with greater proportions of people with lower incomes or minoritized racial and ethnic groups, although reducing retailer-to-retailer proximity and capping the number of retailers may be more influential in terms of equitably reducing the number and location of retailers within a jurisdiction. The approach best suited to reduce disparities may vary based on the population demographics of a jurisdiction and the characteristics or type of community (rural, urban, suburban). However, this finding should not deter tobacco control practitioners from taking action to reduce the type, number, and location of tobacco retailers and evaluating and reporting on the impact of these policies on tobacco use among people experiencing disparities.

Significantly raising tobacco prices is the single most consistently effective tobacco prevention intervention for reducing tobacco use in the general population. Further, price increases are particularly effective among youth and people of lower SES. Given that most people initiate tobacco product use as youth, raising tobacco product prices could help reduce tobacco use among all population groups, including those that have higher tobacco use prevalence. Tobacco control practitioners and researchers could further expand the evidence base by working with jurisdictions that raise tobacco product prices to evaluate and report on the impact of these policies among people experiencing disparities in tobacco use. Given the rapidly changing tobacco product market in the United States, research is also needed to better understand the potential differential impacts of pricing policies on the use of e-cigarettes and other noncombustible tobacco products to inform future efforts.

Evidence supports prohibiting the sale of flavored tobacco products to reduce initiation and increase tobacco cessation at the population level. Prohibiting the sale of flavored products is also expected to lead to a reduction in tobacco-related disparities. The effect of menthol cigarette sales restrictions is expected to be particularly impactful among people from minoritized racial and ethnic groups. Although promotion of cessation services can aid with implementation of all tobacco control policies and maximize their impact, it is strongly recommended that cessation services be accessible and promoted when implementing policies that raise the price of tobacco products or that prohibit the sale of flavored tobacco products. It is also recommended that these policies continue to be evaluated and that surveillance systems continue to be updated to allow for ongoing monitoring of progress in reducing tobacco-related health disparities and to better understand whether complementary interventions may be needed to further reach specific population groups.

In recent decades, evidence has been accumulating on the effectiveness of various tobacco control policies in reducing tobacco use in the general population and in some population groups, such as youth or people with lower incomes. The current literature is limited by the scope of populations that are studied and an incomplete understanding of policies that may best complement one another (Main et al. 2008; Hatzenbuehler et al. 2014; Daley et al. 2021b).

## Community-Level Efforts and Programs

Critical components of community-level programs for reducing the prevalence of tobacco use include preventing initiation and promoting abstinence and quitting among adults and youth (CDC 2012c). Providing cessation resources and conducting mass media campaigns (CDC 2012c) are two strategies that could reduce tobacco-related health disparities. Unfortunately, according to the American Lung Association’s 2023 State of Tobacco Control report, 40 of 50 states received an “F” in tobacco prevention and cessation funding, and only 5 states received an “A” (American Lung Association 2023). The American Lung Association’s grading of state-level cessation access (based on Medicaid coverage of tobacco dependence treatment, state employee health plan coverage of treatment, and quitline funding) is not much better, with only 6 states receiving an “A” grade, and 24 receiving a “D” or an “F.” Moreover, cultural and linguistic adaptations of state-level cessation resources and mass media campaigns for populations that are disproportionately affected by tobacco are somewhat limited.

### Tobacco Quitlines

Quitlines were developed, evaluated, and then disseminated beginning in the late 1980s and 1990s in response to perceived health inequities faced by people who smoked, particularly the lack of access to effective support for quitting smoking (Orleans et al. 1991; Lichtenstein et al. 1996). The initial goal of quitlines was to create a system that could provide easily accessible and evidence-based support for all people who want to quit smoking. Evidence regarding the effectiveness of quitlines for cessation was reviewed in the 2020 Surgeon General’s report on smoking cessation, which concluded that “proactive quitline counseling, when provided alone or in combination with cessation medications, increases smoking cessation” (USDHHS 2020, p. 11).

The 2020 Surgeon General’s report also reviewed the evidence for quitlines as a population-based approach to cessation and concluded that “tobacco quitlines are an effective population-based approach to motivate quit attempts and increase smoking cessation” (USDHHS 2020, p. 11). Multiple studies have found cessation quitlines to be highly cost-effective relative to other commonly used interventions to prevent disease (Tomson et al. 2004; Hollis et al. 2007; Fiore et al. 2008; Reisinger et al. 2019). State quitlines can also play an important role in (1) educating callers about the available coverage from their health insurer for cessation services; (2) referring callers to community-based cessation services; and (3) supporting and increasing provider cessation interventions by being a resource for additional, more intensive cessation counseling (CDC 2014). Taken together, these elements underscore the need for “adequately funding and promoting tobacco quitlines to enable their operations and services to function at levels sufficient to maximize their reach and impact” (USDHHS 2020, p. 660).

In the 1990s and early 2000s, a nationwide quitline infrastructure was created, including a single national portal number (1-800-QUIT-NOW), which launched in 2004 (USDHHS 2020); currently, all 50 states, Washington, D.C., and all U.S. territories have quitlines (Keller et al. 2010; North American Quitline Consortium n.d.c). Quitline funding mechanisms have relied principally on state public health funding (including revenue from state cigarette excise taxes and the Master Settlement Agreement), with supplemental funding from CDC, telecommunications support from NCI, and, in some instances, coordination with private and public health insurers (Lemaire et al. 2015).

Quitlines have potential to reduce or eliminate disparities in access to tobacco treatment “by removing barriers to accessing evidence-based treatment (e.g., cost, location, and time)” (Webb Hooper et al. 2019, p. 500). In addition to addressing inequities in access to cessation services, state-based quitlines have focused on maximizing services for population groups experiencing tobacco-related health disparities (North American Quitline Consortium 2016).

Several studies have found that state-based quitlines generate increased rates of cessation treatment utilization and comparable cessation success rates among key populations experiencing disparities (Abrams et al. 2010; Zhu 2011; Rabius et al. 2012; NCI 2017b). NCI Tobacco Control Monograph 22 determined that quitlines could play a role in decreasing disparities related to both treatment access and cessation, including among racial and ethnic groups (NCI 2017b). For example, a RCT conducted by the American Cancer Society investigating the effectiveness of quitlines found that quit rates were similar between Black and White people (Rabius et al. 2012). Studies in California, Texas, Louisiana, and Washington, DC have shown that proportionately more African American people than White people who smoke use quitlines (Zhu et al. 2011; Rabius et al. 2012). In contrast, rates of use of quitlines were comparable between LGBT adults who smoked and heterosexual adults who smoked, but GBT males who smoked reported less awareness of the availability of quitlines (Fallin et al. 2016).

The benefits to health equity of certain quitline services may depend on the larger availability of cessation support within communities. For example, when NRTs were first introduced, they were seldom covered by health insurers (McAfee et al. 2015), which posed issues for equitable access. In the early 2000s, many quitlines introduced free NRT initiatives in which callers meeting specific eligibility criteria could receive medication via mail order or pharmacy voucher (North American Quitline Consortium 2015). Multiple studies showed that in the environment of relative scarcity for NRT in the United States, this approach markedly increased calls to quitlines and quit success of quitline callers (An et al. 2006; Cummings et al. 2006; Fellows et al. 2007; Hollis et al. 2007). However, studies in other settings have had different results. A study in the United Kingdom a decade later found that the addition of NRT or additional proactive calls to quitline services did not produce the same improvements (Ferguson et al. 2012). One explanation for this finding may be that, unlike in the United States, NRT in the United Kingdom has been strongly integrated into the national health system such that all people who smoked could easily access free NRT from general practitioners and pharmacies (McAfee et al. 2012).

#### Specific Populations

##### Populations with Mental Health Conditions

Smoking is two to three times more prevalent among people with mental health conditions (Center for Behavioral Health Statistics and Quality 2020) compared with people without such conditions, and mental health service providers have been less engaged in providing cessation assistance than other healthcare providers (Prochaska et al. 2017). State-based quitlines have indicated that a high percentage of callers report mental health conditions (Hebert et al. 2011; Lukowski et al. 2015; Vickerman et al. 2015a; North American Quitline Consortium 2021). Many state quitlines have created tailored programs for these callers. An evaluation of tailored programs from the two largest quitline service providers suggests that callers with self-reported mental health conditions benefit from both standard and tailored programs, with higher engagement levels observed for the tailored program. However, no statistically significant differences in abstinence rates were observed in a preliminary analysis of cessation outcomes, potentially due to small sample sizes and low response rates (Morris et al. 2021).

##### American Indian and Alaska Native Populations

American Indian and Alaska Native populations have the highest prevalence of smoking of commercial tobacco of any racial or ethnic group (Cornelius et al. 2022). Many quitlines train counselors in cultural competency, including training regarding American Indian and Alaska Native cultures and ceremonial tobacco use (CDC 2014; North American Quitline Consortium 2021).

Some studies have examined quitline utilization and cessation success rates among American Indian and Alaska Native populations, as well as the use and success rates of culturally tailored interventions. A study of data collected from 2012 to 2014 across 14 states by a multistate quitline service provider showed that 3.5% of callers were American Indian and Alaska Native people (Lukowski et al. 2016); these callers were predominantly American Indian and represented 47 tribes.

A study from the California Smokers’ Helpline found that the proportion of quitline callers who were American Indian and Alaska Native was comparable to the American Indian and Alaska Native population in California who smoked (4.6% vs. 4.3%) (Lienemann et al. 2021). This study also compared the engagement and quitting behaviors of American Indian and Alaska Native callers with that of White callers. All callers received the helpline’s standard, individualized counseling protocol, which was delivered by staff trained in cultural competency. Compared with White callers, American Indian and Alaska Native callers were more likely to engage in counseling and make a quit attempt (adjusted odds ratio [aOR] = 1.39; 95% CI, 1.06–1.81), and had similar odds of quitting for 180 days (aOR = 0.95; 95% CI, 0.69–1.31).

Another study comparing cessation outcomes between American Indian and Alaska Native and White quitline callers in Arizona found that the two groups had similar rates of 30-day cessation (based on self-report) at 7-month follow-up (Yuan et al. 2020).

##### Populations of Lower Socioeconomic Status

People who smoke and are of lower SES have been a population group of focus for many quitlines because of their higher prevalence of smoking, barriers to healthcare access, and other factors that can make cessation more challenging for this population group (North American Quitline Consortium 2016). In the face of often limited funding, some state quitlines previously prioritized services for callers who were uninsured or enrolled in Medicaid, providing a more comprehensive set of services (e.g., multisession counseling, free NRT) to these callers (North American Quitline Consortium 2016). Several studies have shown the promising effects of quitlines for smoking cessation among people who smoke and have lower incomes (Vidrine et al. 2013; Bernstein et al. 2016; Slater et al. 2016; Fraser et al. 2017). Another study found that people with lower incomes who called a quitline were less likely to quit using smokeless tobacco than their counterparts with higher incomes (Mushtaq et al. 2015).

Certain programmatic characteristics of quitlines may enhance the acceptability and effectiveness of services for callers of lower SES. For example, state quitlines provide free services to callers and many offer free starter kits of cessation medications, often sent by mail. Quitlines have also experimented with additional ways to increase engagement with callers of lower SES. For example, the California Smokers’ Helpline Medi-Cal Incentives to Quit Smoking program offered a modest financial incentive ($20) for calling the quitline (not contingent upon quitting) as well as direct mailings to Medi-Cal (California Medicaid) members and free NRT (Anderson et al. 2018; Vijayaraghavan et al. 2018b). Studies evaluating the Medi-Cal Incentives to Quit Smoking program found that these approaches were effective at increasing quitline calls from Medi-Cal members as well as short- and long-term abstinence, with some differences in engagement with different approaches by race and ethnicity (Saw et al. 2018b; Tong et al. 2018b; Cummins et al. 2023). In addition, increased quitline utilization was seen among women of reproductive age and pregnant women who were enrolled in Medi-Cal (Dove et al. 2018).

##### Population Groups that Use Menthol

Use of mentholated tobacco products has not been routinely measured during the quitline intake process, so less is known about quitline reach among people who smoke menthol cigarettes. One study of Minnesota’s quitline reported that 30.7% of callers who smoked used menthol cigarettes and estimated a reach ratio (percentage of callers in the study who smoked menthol divided by the percentage of people in Minnesota who smoked menthol) of 1.12 (95% CI, 0.99–1.25), indicating proportionate representation of people who smoke menthol among quitline callers (D’Silva et al. 2021). This study also found that callers who smoked menthol cigarettes were more likely to be young, female, Black or African American or Hispanic, and live in an urban area. Service utilization patterns were similar between callers who used menthol and nonmenthol cigarettes, except callers who used menthol cigarettes were more likely to enroll in text messaging. Quit outcomes were not reported.

In 2022, about one-third (35%) of state quitlines reported using a specific treatment protocol for individuals who use menthol products, and 3 state quitlines reported use of an incentive program for these callers (North American Quitline Consortium 2023). Bourne and colleagues (2023) described Vermont’s experience with an incentive program which offered a monetary incentive for counseling call completion to those callers that used menthol tobacco products. During the 14-month evaluation period, 58% of enrollees in the menthol incentive protocol completed at least 3 counseling calls compared to 38% of enrollees in the non-incentive protocol. Quit outcomes were not reported.

#### Quitline Reach and Engagement

In 2015, about half of adults who currently smoked reported a past-year quit attempt (Babb et al. 2017). Among adults with a past-year quit attempt and those who successfully quit in the last 2 years, about 7% reported using counseling and about 30% reported using cessation medication (Babb et al. 2017). Among those who used counseling, 4.1% used a telephone quitline. In an analysis of 2014–2015 TUS-CPS data, an estimated 3.5% of U.S. adults who currently smoked and made a past-year quit attempt used a telephone quitline (USDHHS 2020). Generating calls to quitlines has sometimes been a challenge, and, as found in one Colorado study, interest in calling a quitline may vary based on sociodemographic characteristics, including ethnicity, insurance status, and sexual orientation (Burns et al. 2011).

Some strategies have been employed to increase quitline reach and engagement. For example, mass media campaigns that encourage calls to quitlines have been successful in increasing quitline calls across multiple populations (Davis et al. 2018). Using ads that are directed to specific population groups, such as individuals with mental health conditions, has been successful (Prochaska et al. 2019). In most states, quitline promotions via media campaigns are moderated based on budget allocations which, in turn, correlate to the volume of calls that can be managed. Funding levels for quitline promotion and quitline utilization are highly correlated (R +0.74; p <0.001) (Cummins et al. 2007). Additional reviews of mass media campaigns are found elsewhere in this chapter.

Additional strategies to increase calls to quitlines include expansion of services to new communication technologies, language and cultural adaptation and promotion, and healthcare-mediated connection to quitlines. These strategies are discussed in greater detail in the sections that follow. Dyadic engagement, in which assistance is solicited from support people who do not smoke (i.e., family members and friends) during the process of engaging people in quitline interventions, has also been examined as a way of increasing enrollment in quitlines. One study found that as little as one phone intervention with family members and friends who do not smoke more than doubled quitline enrollment among people who smoke (from 6% to 15%) (Patten et al. 2017). Dyadic interventions are explored further elsewhere in this chapter.

Internationally, quitlines have been promoted by requiring that the quitline number be included on graphic warning labels on cigarette packages. Using intake data, a Canadian quasi-experimental pre–post study of seven provincial quitlines examined the effect of including quitline numbers on cigarette package labels on quitline reach and reach equity in three selected populations of concern: young males, those with a high school education or less, and those living in rural areas (Baskerville et al. 2015a). After the new warning labels were introduced, 86% of callers indicated that they saw the quitline number on the labels. Call volume almost tripled, with increased reach equity for young males (p <0.0001) and those with a high school education or less (p = 0.004). WHO has determined that quitlines can play an important role in overcoming inequities between the availability of cessation treatment support in higher income countries and the lack of availability in lower and middle-income countries (WHO 2011).

Measuring the effect of quitlines via call volume alone may underestimate their population impact. There is evidence of additional effects from the interaction between mass media campaigns and the quitline services promoted in such campaigns. These synergistic effects include increases in population-level quit attempts and success that are markedly larger than those attributable solely to quitline calls (Ossip-Klein et al. 1991; McAfee et al. 2013). Increased quit attempts motivated by campaign exposure but made without calling the quitline are the primary driver of these population effects. This benefit is explored in greater depth elsewhere in this chapter.

##### Technology-Mediated Quitline Services

The revolution in digital communication technologies has created both opportunities and challenges for quitlines in engaging populations affected by tobacco-related health disparities. Opportunities include technology-mediated services that can make it even easier for people to get immediate, customized, and interactive cessation support. Such services include web-based, texting, and chat programs, as well as emerging approaches such as smartphone applications and social media (USDHHS 2020). The evidence regarding the effectiveness of cessation interventions delivered using these technologies was reviewed in the 2020 Surgeon General’s report, which concluded that web- and text-based interventions are effective in increasing smoking cessation (USDHHS 2020). Challenges in leveraging digital communication technologies to engage groups disproportionately affected by tobacco-related disparities include state variation in service availability, uneven availability of broadband Internet service, and differential engagement with these service modalities among different population groups.

Many state quitlines have incorporated a suite of digital cessation support options (Zbikowski et al. 2008) and offering multiple modality options is now a common practice for most U.S. state quitlines (North American Quitline Consortium n.d.a). For example, in 2014, ClearWay Minnesota changed its suite of quitline services so that clients could choose to use the telephone quitline or one or more individual QUITPLAN services including an NRT starter kit, text messaging, an email program, or a quit guide. In addition, the quitline services website was redesigned, online enrollment was added, and a new advertising campaign was created and launched. An evaluation of the impact of the changes to the program found substantial increases in the quitline’s reach, with a 169% increase in enrollment compared with the year prior to the QUITPLAN model, as well as strong quit outcomes (Keller et al. 2016). Similar program expansion and promotion in two additional states (Oklahoma and Florida) was also found to be associated with increased treatment reach (Keller et al. 2016).

The impact of increasing reliance on digital delivery of cessation support on tobacco-related health disparities is unclear. Initial studies of web-based interventions suggest that when offered multiple options for accessing services, most quitline callers still opt for live phone services (Zbikowski et al. 2008), and that minoritized racial and ethnic groups tend to not use web-based quitline services, as described next.

In a 2015 study of enrollment and utilization patterns in five state quitlines that offered web-only services as an option, Webb Hooper and colleagues (2019) found lower rates of web enrollment and web-only service utilization among African American, Hispanic, and American Indian and Alaska Native clients compared with White clients. In the same study, utilization of web-only services was also associated with increasing level of education and annual income and inversely associated with age.

A different study of subscribers to NCI’s text message-based cessation support program, SmokefreeTXT, examined program enrollment, engagement, and cessation by race (N = 8,487) (Robinson et al. 2020). Program enrollment rates matched race proportions of people who smoke in the general population. Black subscribers were more likely to complete the program than White subscribers (aOR 1.71; 95% CI, 1.43–2.06). Program engagement (assessed by responsiveness to program prompts) and end-of-program abstinence were lower among Black subscribers (abstinence: 4% for Black people and 7% for White people), though quit status assessment completion rates were low. Such differential utilization of, and engagement with, digital service options, as seen in these studies, has the potential to exacerbate disparities in quitting, particularly if quitlines begin to rely more heavily on potentially less expensive digital services in the face of diminishing budgets (Saul et al. 2012).

##### Language and Culture Adaptations

Increasing linguistically and culturally appropriate cessation services is another potential way to increase quitline engagement among populations disproportionately affected by tobacco. Most state quitlines can provide cessation support in multiple languages via interpreters (North American Quitline Consortium 2016). In addition, language-specific quitlines are available in Spanish and Asian languages, both of which have been successfully promoted in linguistically and culturally relevant ways (see “Mass Media Campaigns” section for more detail).

The Spanish Language quitline portal (1-855-DÉJELO-YA) was developed as a companion to 1-800-QUIT-NOW and was integrated into the existing infrastructure of state quitline service providers; it is promoted with Spanish-language ads in Spanish media channels. A community-based quality improvement process was used to develop and deliver a media campaign promoting DÉJELO-YA in New Mexico. Pre–post quitline data showed that the project was associated with a 31% increase in Spanish-speaking calls to DÉJELO-YA, compared with a 3% increase among non-Hispanic calls to the English quitline (Dilley et al. 2020). Quit success increased from 33% to 46% among Spanish speakers but did not change among English speakers. Another study in Colorado examined quitline call volume before and during a culturally relevant Spanish-language media campaign that promoted the quitline and found increased quitline calls from Latino people during the campaign; furthermore, more Latino callers to the quitline spoke Spanish during the campaign compared with Latino callers before the campaign (Burns and Levinson 2010).

The Asian language quitline, currently operated by the University of California, San Diego with funding from CDC under the name “Asian Smokers’ Quitline” (ASQ), provides cessation services across the United States in Mandarin, Cantonese, Korean, and Vietnamese. Before formation of the Asian language quitline, Zhu and colleagues (2012) conducted an RCT in California which demonstrated the efficacy of culturally tailored and language-adapted telephone-based counseling among Asian American people who smoked (see “Individual Interventions” section for more detail).

A more recent study (Chen et al. 2021) examined the service utilization and outcomes of the ASQ from 2012 through 2019 and found that the 14,073 enrollees learned of the quitline primarily from Asian-language newspapers; 37% of callers were uninsured and 74% opted to use quitline-supplied pharmacotherapy. The 6-month abstinence rate was 28.6%. A California study found that culturally appropriate and community-focused promotion of the ASQ resulted in increased calls to the quitline by Medi-Cal (California Medicaid) enrollees. Promotion efforts included in-language materials from the Medi-Cal Incentives to Quit Smoking project (including direct-tomember mailings), utilizing the California quitline’s Asian print media campaign, press releases to ethnic media incorporating Lunar New Year messages, and community-based outreach such as in ethnic supermarkets (Saw et al. 2018b).

##### Healthcare Connections to Quitlines

Healthcare referrals to quitlines, in which a clinician provides a patient with direct or indirect connection to a quitline, is another strategy to increase quitline engagement and connect people to evidence-based cessation supports. Recent community-based healthcare system trials have documented quitline enrollment rates at markedly higher levels than those seen when quitlines are promoted in standard fashion. One example of a health system-level strategy designed to link patients to quitline cessation resources is the Ask, Advise, Connect (AAC) model. Using this model, trained medical staff “Ask” patients about their smoking status, “Advise” those who smoke to quit, and offer to immediately “Connect” individuals with quitlines through an automated link within the patient’s electronic health record (EHR).

This approach was evaluated in a 34-month implementation trial from 2013 to 2016. The trial was conducted in a large safety-net healthcare system with 13 community clinics that provided care to patients who were predominantly from minoritized racial and ethnic groups. The proportion of all identified adults who smoked who enrolled in treatment was 11.8%, which was high relative to engagement rates for more traditional referral-based approaches (Pineiro et al. 2020). Self-reported abstinence at 6 months was 16.6%, and biochemically verified abstinence was 4.5%—in line with reports from other studies of quitline-delivered treatment (Pineiro et al. 2020).

Similar results were found in a trial conducted in 30 primary care clinics in which reach and effectiveness were measured before, during, and after the implementation of EHR workflow changes to facilitate electronic quitline referrals. Quitline referrals increased from 1.7% to 11.3%. Referral rates were especially high for women, African American patients, and patients enrolled in Medicaid. Referral rates diminished over the 8 months after the implementation period but remained higher than they were prior to the project (Baker et al. 2021).

#### Summary and Recommendations

The literature on the effectiveness of quitlines for cessation highlights the accomplishments and potential of quitlines to reduce disparities in access to cessation services. Evidence also indicates that the reach and effectiveness of quitlines can be as good, or better, for key population groups experiencing tobacco-related disparities as they are for the overall population of people who smoke. However, quitline use by some population groups may be limited by barriers to adoption and maintenance, and in particular, restrictions on funding for state-based programs and policies or programs designed to limit barrier-free access to the range of quitline services including live support, digital support, and medications. Such barriers may decrease the impact of quitlines on increasing successful quitting. Accordingly, more research is needed to determine the best approaches and policies to maximize the reach, utilization, and effectiveness of quitlines, including both digital and telephonic resources, among diverse population groups.

Evidence to date strongly suggests that traditional phone and digital quitline services, as currently promoted and delivered, have the capacity to reach and benefit populations who experience tobacco-related health disparities. Although there is likely some additional benefit to be gained from further research and implementation of services with additional cultural specificity, increasing the reach and dissemination of existing proven services, with special attention to ensuring use by priority populations, may be the most important current health equity task for quitline services. Further understanding of the policy, resource, promotional, and programmatic barriers to accomplishing this task is critical.

In the ensuing decade, the primary focus will not be on whether quitlines, including new digital services, can reduce health disparities, but rather on how to ensure that the mix of services provided by quitlines and the promotion of such services and of quitlines are designed, evaluated, and delivered in a manner that maximally leverages their potential to reduce tobacco-related health disparities. Future evaluations of cessation services delivered via quitlines should include data collection and analysis by race and ethnicity and SES, as well as other disparity population group characteristics of importance such as age, sexual orientation, gender identity, mental health condition status, and rural residency.

In addition, analyses should examine how the reach, engagement, and effectiveness of quitlines are affected by (1) the communication channel used to provide services (e.g., live phone, text messaging, web-based, smartphone app, or automated interactive voice response); (2) intervention elements and characteristics; and (3) dosing effects, particularly among priority populations. In some cases, effective evaluation may require oversampling of smaller population groups, such as American Indian and Alaska Native people, Asian people, and people who identify as LGBTQI+ to have sufficient power to detect or rule out differences in reach or effectiveness.

Other policy interventions that may improve quitline use include changes in healthcare systems to prompt, guide, and incentivize tobacco cessation treatments; integration of access and feedback between healthcare systems and quitline service providers (including with referral capacity through EHRs); enhanced capacity of quitlines to leverage health insurance coverage to pay for services and decrease reliance on public health funds; promotion of evidence-based treatments via technology-based or technology-assisted platforms and/or the integration of quitline services with other technologies; increased dose and duration of media campaigns that promote quitlines as a cessation resource; increased funding of state tobacco control programs; and research to improve the long-term effectiveness of evidence-based treatments via individually tailored approaches (CDC 2014, 2020; Athar et al. 2016).

The 2020 Surgeon General’s report on smoking cessation underscores the need to enhance the reach of existing evidence-based programs, particularly for populations with distinct needs (USDHHS 2020). Achieving this objective is likely to require the universal provision of comprehensive quitline services with robust promotion and sufficient funding so that these services can be obtained by all who need them.

### Mass Media Campaigns

This section addresses the role of mass media campaigns in decreasing tobacco-related health disparities. Historically, media campaigns have often been a part of broader population-based tobacco control programs that discourage smoking initiation among youth and young adults, encourage quitting among people who smoke (NCI 2008; USDHHS 2014, 2020), and strengthen social norms against tobacco use (NCI and WHO 2016). National evidence reviews conducted over the past two decades have found that media campaigns can prevent smoking initiation and increase smoking cessation at the population level (Table 7.5). Most recently, the 2020 Surgeon General’s report summarized evidence showing that smoking cessation can be increased by implementing high-impact mass media campaigns that have sufficient reach, frequency, and duration (USDHHS 2020).

Table 7.5 Key conclusions, findings, and recommendations about mass media campaigns

Source | Conclusions, findings, or recommendations
Conclusions from Surgeon General’s Reports
USDHHS (1998) | “Numerous strategies are needed to control tobacco use among racial/ethnic youths: restricting minors’ access to tobacco products, establishing culturally appropriate school-based programs, and designing mass media efforts geared to young people’s interests, attitudes, expectations, and norms. Recent provisions of the Synar Amendment, designed to prevent minors’ access to tobacco products, and the FDA regulations aimed at reducing the access to and appeal of tobacco products to young people are intended to reduce tobacco use among all youth, including members of racial/ethnic minority groups” (p. 14).
USDHHS (2012) | “Coordinated, multicomponent interventions that combine mass media campaigns, price increases including those that result from tax increases, school-based policies and programs, and statewide or community-wide changes in smoke-free policies and norms are effective in reducing the initiation, prevalence, and intensity of smoking among youth and young adults” (p. 8).
USDHHS (2014) | “The evidence is sufficient to conclude that mass media campaigns, comprehensive community programs, and comprehensive statewide tobacco control programs prevent initiation of tobacco use and reduce the prevalence of tobacco use among youth and adults” (p. 12).
USDHHS (2020) | “The evidence is sufficient to infer that mass media campaigns increase the number of calls to quitlines and increase smoking cessation” (p. 12).; “The evidence is sufficient to infer that comprehensive state tobacco control programs reduce smoking prevalence, increase quit attempts, and increase smoking cessation” (p. 12). Mass media campaigns are part of comprehensive state tobacco control programs.
Findings from National Cancer Institute Monographs
NCI Tobacco Control Monograph 19 (2008) | “Evidence from controlled field experiments and population studies shows that mass media campaigns designed to discourage tobacco use can change youth attitudes about tobacco use, curb smoking initiation, and encourage adult cessation. The initiation effect appears greater in controlled field experiments when mass media campaigns are combined with school-and/or community-based programming. Many population studies document reductions in smoking prevalence when mass media campaigns are combined with other strategies in multicomponent tobacco control programs” (p. 12).
NCI and WHO Tobacco Control Monograph 21 (2016) | “Well-designed and -implemented anti-tobacco mass media campaigns are effective in improving understanding about the health consequences of tobacco use, building support for tobacco control policies, strengthening social norms against tobacco use, and reducing tobacco consumption among youth and adults” (p. 13).
NCI Tobacco Control Monograph 22 (2017b) | Among youth, “[A]nti-tobacco TV campaigns can effectively reduce smoking prevalence among the general population, but there is less evidence about their effectiveness among different population groups. For youth, communication inequalities may contribute to differences in awareness of tobacco prevention campaigns across groups but may not affect receptivity to campaigns or the impact of campaign messaging on attitudes, beliefs, and behaviors. … Low-SES youth and racial/ethnic minorities are receptive to campaign messages, and campaigns can influence knowledge, attitudes, and beliefs among diverse groups. …[D]ifferences in message processing should be considered in campaign development. Further, campaigns with the strongest short- and long-term behavioral effects among low-SES and racially diverse youth were often complemented by community, school, or state programs that supplemented campaign messaging with other tobacco control programming” (pp. 418–419).; Among adults, “[C]ampaigns with (1) high exposure, targeted media efforts; (2) additional tobacco-related program components; or (3) language-appropriate and/or culturally tailored messaging can be effective and may reduce potential communication inequalities that lead to gaps in tobacco-related knowledge. Additionally, campaigns with graphic and emotionally arousing messages can also stimulate quitting among racial/ethnic minorities and low-SES groups. By ensuring that additional supportive resources are available, such as quitline support, free NRT, and other community-based programs and policies, campaign effectiveness can be improved among diverse populations” (p. 419).
Recommendations from Community Preventive Services Task Force
Community Preventive Services Task Force (2013) | The Community Preventive Services Task Force recommends “mass-reach health communications interventions based on strong evidence of effectiveness in decreasing the prevalence of tobacco use; increasing cessation and use of available services such as quitlines; and decreasing initiation of tobacco use among young people.”

Notes: FDA = U.S. Food and Drug Administration; NRT = nicotine replacement therapy; SES = socioeconomic status.

Given their proven positive impact on tobacco prevention and control at the population level, the role of mass media campaigns in decreasing tobacco-related health disparities is especially critical to examine. From a historical perspective, the 1998 Surgeon General’s report, Tobacco Use Among U.S. Racial/Ethnic Minority Groups, indicated that mass media campaigns were an effective strategy to address disparities, but the report cautioned that campaigns for “racial and ethnic youth” should be “geared to young people’s interests, attitudes, expectations, and norms” (USDHHS 1998, p. 14). The 2012 Surgeon General’s report cautioned that although tailoring message content to specific population groups may be more persuasive, the finite resources of most public health campaigns mean that the extent of tailoring and segmentation “needs to be weighed carefully against goals of maximizing campaign exposure” (USDHHS 2012, p. 635).

NCI Tobacco Control Monograph 22 provides the most recent comprehensive and systematic review of the evidence related to tobacco-related health disparities and tobacco countermarketing campaigns, including summary findings from literature published between 1990 and 2014. The monograph concluded that mass media campaigns are effective at influencing tobacco-related knowledge, attitudes, and beliefs, as well as stimulating quitting for the general population, minoritized racial and ethnic groups, and socioeconomically disadvantaged populations (NCI 2017b).

The review in NCI Tobacco Control Monograph 22, as it pertained to adults and tobacco-related disparities, found that “campaigns with (1) high-exposure, targeted media efforts, (2) additional tobacco-related program components, or (3) language-appropriate and/or culturally tailored messaging can be effective and may reduce potential communication inequalities that lead to gaps in tobacco-related knowledge” (NCI 2017b, p. 419). The monograph also emphasized that mass media campaigns are most effective at increasing cessation for socioeconomically disadvantaged populations when both state and community-based programs that support behavior change complement countermarketing media campaign efforts.

NCI Tobacco Control Monograph 22 also reviewed several health disparity frameworks, including the “Structural Influence Model,” a theoretical framework that explains how communication may differentially affect tobacco use among minoritized racial and ethnic groups. Based on social epidemiologic and media theories, this framework posits that “social determinants [of health] (such as SES and geographic location) act through social networks and demographic characteristics (such as age and gender) to influence how individuals access and comprehend health information” (NCI 2017b, p. 363). An implication of this framework is that, given how demographic characteristics (such as age) inform how media channels are accessed (e.g., adolescents tend to use different social media applications than adults do), rigorous evaluation studies are warranted to inform the reach and effectiveness of tobacco countermarketing mass media campaigns for priority populations.

Numerous mass media campaigns have targeted a broad array of audiences, ranging from the general public to people who use tobacco products (usually with a focus on cigarettes) to a range of racial and ethnic, sexual orientation and gender identity, and lower SES population groups. Campaigns have been conducted at different levels of intensity and duration, by a variety of governmental and nongovernmental organizations, and with different aims, including preventing the initiation and progression of smoking in youth and young adults, promoting smoking cessation and use of evidence-based support, increasing support for tobacco control policies, and shifting the attitudes of community members toward denormalizing tobacco use and tobacco industry practices (NCI 2008).

Some members of priority populations may have less exposure to campaign messages, insufficient literacy to process information from a campaign, or inadequate resources to take action toward quitting. These inequalities may, in turn, influence tobacco product use, initiation, and cessation among diverse population groups. The intersection of multiple sociodemographic categories (such as an individual who identifies as LGBTQI+ and Multi-Race) may further complicate tobacco-related health disparities (Potter et al. 2021). Intersectionality may make it more challenging to develop and deliver targeted media campaigns and community-based interventions based on a single sociodemographic characteristic because people who use tobacco may identify with multiple population groups.

This section summarizes the characteristics of tobacco countermarketing mass media campaigns from the last 15–20 years, including their general and tailored strategies and specific targeted approaches to communication. The section also reviews evidence from critical studies regarding countermarketing media campaigns. Because the published literature is limited, this section does not review in-depth evidence regarding digital and social media campaigns as they relate to tobacco-related health disparities. The section concludes with recommendations for building the evidence base for using mass media strategies as part of a comprehensive effort to reduce and eliminate tobacco-related health disparities.

#### Strategies for Tobacco Countermarketing Media Campaigns

CDC defines tobacco countermarketing as media campaigns that use existing commercial marketing strategies to reduce the prevalence of tobacco use (CDC 2003). Currently, media campaigns employ several strategies to address disparities in tobacco use. Campaigns aimed primarily at geographically defined populations (such as states) generally use one or more of the following campaign development approaches to address tobacco-related health disparities: (1) crafting ads that include strong priority population representation, with messaging developed and tested to ensure appeal and generate action across most sociodemographic population groups of focus; (2) using tailored or modified messaging in some ads (including language translation and/or cultural specificity) to enhance reach and effectiveness for specific priority populations; and (3) designing a campaign to specifically address tobacco use solely among members of a disproportionately affected population group. In addition to the development of countermarketing ads and materials, all three of these approaches require careful attention to purchasing strategies for ad placement to ensure that ads are seen by target priority populations, along with evaluation strategies that include outcomes among priority populations (Cowell et al. 2009; Richardson et al. 2011).

NCI Tobacco Control Monograph 22, which summarizes an evidence review through 2014, concluded that “the available evidence is inconsistent about the degree of effectiveness of media campaigns among socioeconomically disadvantaged populations, particularly the most highly disadvantaged” (NCI 2017b, p. 366). Similarly, the monograph’s review of evidence on targeted campaigns through 2014 specifically designed for diverse racial and ethnic groups was inconclusive and limited. Emerging research and practice support the idea that campaigns, whether general or targeted, should be adapted to better disseminate tobacco prevention and control messages among socioeconomically disadvantaged populations (NCI 2017b).

Targeted communication approaches may be based on demographic characteristics; for example, these campaigns may target people according to their age, gender, race or ethnicity, geographic region, or a combination of characteristics. Innovative approaches that do not focus on demographic characteristics, such as targeting people by psychosocial factors or their use of specific tobacco products, are emerging and have shown some positive effects in addressing tobacco use among disproportionately affected groups; they may also affect multiple sociodemographic groups simultaneously (Ling et al. 2014; Fallin et al. 2015b; Kalkhoran et al. 2016; Kowitt et al. 2018; Wagner et al. 2018).

#### Communication Approaches for Specific Focus Populations

Objectives related to reaching populations affected by health disparities have been included in the development and execution of many of the large-scale, broad-based media campaigns of the twenty-first century (Vallone et al. 2009; McAfee et al. 2017; Saw et al. 2018b; Guillory et al. 2022). There is also growing experience with smaller campaigns that are focused on a particular population group, referred to in this section as focus populations. Focus populations for media campaigns can include groups of a particular age, race or ethnicity, sexual orientation or gender identity, mental health condition, SES, and geographic area, or combinations of these groups. Mass media campaigns in the twenty-first century are designed to reach large groups of people through multiple media channels, including newer channels such as digital and social media. Although ad buys on various platforms typically require specification of a primary audience, this does not necessarily preclude reach to other groups, as there may be overlap in media viewing patterns between groups.

This section first presents a media campaign topography based on age, as this is the largest differentiator in most national and state campaigns, particularly with respect to campaign goals (initiation prevention vs. cessation) and media channels. Some population groups’ findings are presented within the context of the age divisions. Following this section, additional findings are presented in sections on race and ethnicity and mental health conditions. The largest evidence base for effectiveness of specific approaches is for campaigns based on (1) age and (2) race and ethnicity.

##### Media Campaigns Designed to Reach People of Specific Ages

Among campaigns directed at specific age groups, those that aim to prevent initiation of tobacco use among youth and young adults have received considerable attention, in part because people in this developmental period are vulnerable to both the initiation and establishment of smoking. These campaigns have also received strong public and policymaker support because of the documented targeted marketing practices of the tobacco industry toward youth (NCI 2008). Although most prevention campaigns aim primarily to influence youth, most cessation campaigns aim primarily to reach adults.

Youth. Several national countermarketing campaigns have focused on youth under 25 years of age. The Truth campaign and The Real Cost campaign are reviewed in this section in addition to a brief discussion of state-based campaigns focused on youth.

Truth. The Truth campaign from the Truth Initiative (until 2015, the American Legacy Foundation) is a national campaign focused on preventing smoking initiation. A 2009 evaluation showed that this campaign effectively prevented smoking initiation among people who never smoked who were Black or African American but not among people who never smoked who were members of other racial and ethnic groups (Cowell et al. 2009). Black and Hispanic youth and young adult viewers of the campaign’s materials discussed the campaign with friends and family members more frequently than did non-Hispanic White youth and young adults (Dunlop 2011). Lower awareness of the campaign was found among people with lower levels of education and among female youth (Vallone et al. 2009). On the other hand, a 2018 evaluation of the Truth Initiative’s Finish It campaign (Hair et al. 2019), which ran from 2014 to 2016, found no moderating effect of key demographic factors (including age, gender, race and ethnicity, or parent education) on the relationship between awareness of the Truth ads and intentions to smoke (Vallone et al. 2018).

The Real Cost. In 2014, FDA launched The Real Cost campaign, the first federally funded education campaign to prevent and reduce tobacco use among youth 12–17 years of age who did not smoke or were tobacco experimenters. Since its launch, several evaluations have shown that the campaign has had a successful overall impact, as it prevented an estimated 380,000–587,000 adolescents from initiating smoking from 2014 through 2016 (Duke et al. 2019), influenced tobacco-related beliefs among youth nationwide (Huang et al. 2017b), and demonstrated cost-effectiveness (MacMonegle et al. 2018).

In an observational longitudinal study, Duke and colleagues (2019) noted that the campaign was associated with a decreased risk of smoking initiation among youth overall, but not among Hispanic youth compared with non-Hispanic White youth. In a separate national study, Huang and colleagues (2017b) found that, although most youth reported negative attitudes toward tobacco products after seeing or hearing the ads, Black youth who recalled The Real Cost campaign slogan were less likely to report negative attitudes toward tobacco products than were White youth (aOR = 0.46; 95% CI, 0.25–0.85). Separately, Delahanty and colleagues (2019) found in a national survey that, 3 years after the campaign’s launch, more than half (58.5%) of middle and high school students reported awareness of The Real Cost campaign. Campaign awareness, however, varied by race and ethnicity, with the highest awareness among non-Hispanic White students and lower awareness among Hispanic and non-Hispanic Black students (p <0.001) (Delahanty et al. 2019). Taken together, these results suggest a need for increased reach of tobacco prevention messages to Hispanic and Black youth.

To complement The Real Cost in the general youth market, FDA has also funded several tailored campaigns designed to reduce tobacco-related disparities among youth and young adult populations who are at risk. For example, Fresh Empire (FDA 2018b) targeted at-risk adolescents from priority populations (including Black or African American, Hispanic, Asian American, and Pacific Islander adolescents) who identify with “hip-hop culture.” Campaign evaluations have demonstrated reach among target populations, greater recall among the focus populations, and youth-reported negative attitudes toward tobacco products after seeing campaign ads (Kowitt et al. 2018; Guillory et al. 2020, 2022). One evaluation study demonstrated that adolescents 13–17 years of age who recalled ads from multiple campaigns (e.g., Fresh Empire, The Real Cost) had higher odds of reporting negative feelings toward tobacco products, suggesting that cumulative crossover campaign exposure may have positive effects (Kowitt et al. 2018). Another campaign, This Free Life (FDA 2022d), which focused on LGBTQI+ people 18–24 years of age, reached and generally resonated with the young adult LGBTQI+ population group (based on perceived ad effectiveness and brand equity) and had a small effect on beliefs involving the social aspects of smoking (Crankshaw et al. 2022). In addition to the campaigns described in the published literature, FDA launched Next Legends in 2022, which focuses on youth e-cigarette prevention among American Indian and Alaska Native youth 12–17 years of age (FDA 2022b). This campaign uses tailored messaging and branding designed to reach American Indian and Alaska Native youth using a largely digital-based media approach.

State-level campaigns. State governments have also invested in campaigns to prevent tobacco use among youth. For example, North Carolina’s Tobacco. Reality. Unfiltered. (TRU) campaign was implemented in 2004–2009 (Kandra et al. 2013). Awareness of this campaign was significantly associated with substantially lower smoking experimentation and current smoking among high-sensation-seeking youth (Kandra et al. 2013). Elsewhere, a randomized community trial of a youth prevention media campaign in four states found no impact on the prevalence of youth smoking overall (Flynn et al. 2010). However, marginal effects were seen on the prevalence of smoking and on the psychosocial mediators of smoking among Hispanic youth, suggesting that the novelty of targeted messaging may have had a greater impact on this underserved population group, even though no effect was seen among African American youth (Flynn et al. 2010). However, the ability to detect a difference in this population-level trial was weakened by concurrent real-world non-research-related mass media campaigns and tobacco control activities.

Adults. A 2017 Cochrane review of media campaigns to promote smoking cessation found evidence that such campaigns were generally effective, with no consistent variation in effect strength by age, gender, education, or race and ethnicity (Bala et al. 2013, 2017). Notably, most campaigns that focused on adults have largely been designed to reach people 55 years of age and younger. Because older adults may respond differently to campaign messaging (McAfee et al. 2013; Cataldo et al. 2015), this may have relevance to age-related disparities in campaign reach and impact (Isenberg et al. 2016; McAfee et al. 2021); however, research is limited in this area. Campaigns have often had secondary foci related to other population groups disproportionately affected by commercial tobacco. The BecomeAnEX, Tips From Former Smokers, and Every Try Counts campaigns are reviewed in this section.

BecomeAnEX. The first major adult, national, branded tobacco countermarketing campaign of the twentieth century, BecomeAnEX was launched in 2008 by the American Legacy Foundation (now Truth Initiative) with funding from the Master Settlement Agreement. The campaign and its evaluation focused on people who smoked and were between 25 and 49 years of age (Vallone et al. 2011b). The campaign also had a goal of encouraging quitting among manual labor and service (“blue collar”) workers and people with lower incomes who smoked, with an emphasis on diverse racial and ethnic groups. Ad placement emphasized media outlets that were popular with the target audiences. Evaluations focused on campaign effects in a cohort of 4,000 adults (18–49 years of age) who smoked in designated media markets with campaign media buys and examined baseline and post-campaign attitudes, awareness of exposure to ads, and quit behaviors (Vallone et al. 2011a). Quit attempt outcomes relied on individual recall of exposure to campaign ads and were thus subject to recall bias. People recalling exposure to campaign ads were 24% more likely to have made a quit attempt (p = 0.048).

Tips From Former Smokers. CDC launched the first federally funded national tobacco education campaign, Tips From Former Smokers (Tips), in March 2012 (McAfee et al. 2013), with the goal of encouraging and supporting smoking cessation among people 18–54 years of age. The Tips campaign features stories from real people and their families who are living with serious long-term health effects from smoking and exposure to secondhand tobacco smoke. All ads from this campaign include the promotion of evidence-based smoking cessation resources (e.g., the national quitline portal).

Research suggests that, from 2012 to 2018, an estimated 1 million people who smoked quit and more than 16.4 million people attempted to quit smoking because of the Tips campaign (Murphy-Hoefer et al. 2020). In addition, studies of the Tips campaign have found increases in calls to quitlines (CDC 2012d, 2013; McAfee et al. 2013; Zhang et al. 2014, 2015, 2016a,b, 2021; Davis et al. 2015; Duke et al. 2015b; Vickerman et al. 2015b; Mann et al. 2020); visits to campaign websites (CDC 2012d, 2013; Davis et al. 2016; Kim et al. 2016a; Shafer et al. 2016); changes in knowledge, beliefs, and cognitions (Duke et al. 2015b); and campaign cost-effectiveness (Xu et al. 2015; Maciosek et al. 2020; Shrestha et al. 2021).

The Tips campaign has several attributes that make it particularly relevant when considering the impact of media campaigns on priority populations. These attributes include the Tips campaign’s long duration, as it has run nationwide for 12–24 weeks annually for more than 10 years with high levels of ad reach and messaging frequency; inclusion of a diverse group of campaign participants, many of whom are from population groups that are disparately affected by tobacco use (CDC n.d.e); use of multimodal media channels, including specific placement designed to reach priority populations (USDHHS 2014); development of culturally and linguistically tailored ads and resources; partnership with governmental, nongovernmental, and healthcare entities to extend the campaign’s relevance, reach, and promotion of cessation resources; and a record of rigorous evaluation and research.

Several evaluations of the Tips campaign have investigated the campaign’s impact on specific population groups. One such study looked at the association between the Tips campaign’s media dose (via Gross Rating Points [GRPs]) and cessation behaviors using data from 2012 through 2015. This study found an association between GRPs and increased quit attempts overall. As the study was not explicitly powered to detect campaign effects among individual population groups, the authors conducted exploratory analyses to test for interactions between the Tips campaign GRPs and population groups of interest. No statistically significant interactions between GRPs and race or ethnicity, education level, or mental health status were observed (Davis et al. 2018).

Another study involving a large, nationally representative sample of U.S. adults who smoke demonstrated an association between an ad’s perceived effectiveness score and prospective quit attempts (Davis et al. 2017). This study reported that non-Hispanic Black and Hispanic adults scored ads higher in perceived effectiveness regardless of the race and ethnicity of the ad participant, and that message characteristics, such as graphic visuals and emotional content, may play a more important role in perceived effectiveness than the race and ethnicity of ad participants.

Additional research has demonstrated that the Tips campaign is associated with increased quit attempts among specific populations of people who smoke, including African American people (McAfee et al. 2017), pregnant women (England et al. 2017), people with mental health conditions (Prochaska et al. 2019), and those with lower educational attainment (Davis et al. 2017). For example, a longitudinal pre–post cohort study of the 2012 Tips campaign (McAfee et al. 2013) modeled changes in quit attempts before and after the campaign for separate racial and ethnic groups; results from the models demonstrated significant pre–post changes in quit attempts among both African American people who smoked (OR = 1.61; 95% CI, 1.01–2.55) and White people who smoked (OR = 1.23; 95% CI, 1.05–1.45). During the 2013 campaign, a randomized trial of regional media markets was conducted to examine the impact of higher doses of the campaign (i.e., 2,400 vs. 800 quarterly GRPs) on quit attempts (McAfee et al. 2017). The study found that African American people were strongly responsive to the increased dose, with quit attempt rates increasing from 31.8% with standard dosing to 50.9% with increased dosing (p <0.01); White people did not experience an increase in quit attempt rates in response to increased dose (33.4% vs. 34.8%; p = 0.23). In other Tips studies, African American people had higher perceived ad effectiveness compared with other groups (Davis et al. 2017) as well as the highest awareness of the Tips campaign (Zhang et al. 2015a). Exposure to the Tips campaign has also been associated with increased smoking cessation among pregnant women overall as well as among specific groups of pregnant women, including those insured by Medicaid and those with less than a high school education (England et al. 2017).

In addition to motivating people who smoke to quit, the Tips campaign also promotes quitlines for smoking cessation support. The immediate impact of the Tips campaign on increasing quitline call volume has been well documented (CDC 2012d, 2013; McAfee et al. 2013; Zhang et al. 2014, 2015, 2016a,b, 2021; Davis et al. 2015; Duke et al. 2015b; Vickerman et al. 2015b; Mann et al. 2020), and several findings address specific populations.

In a study of quitline registrants who called 1-800-QUIT-NOW, Zhang and colleagues (2021) found that those who reported hearing about the quitline from radio ads were more likely to be male, younger, or have more education, whereas those who reported hearing about the quitline from TV ads, which compose the bulk of Tips’ paid media, were more likely to be Black or not of-Hispanic ethnicity or have less education. In a different study, Zhang and colleagues (2014) demonstrated increases in quitline call volume among all population groups, particularly those who were uninsured, during periods that Tips was on air. Similarly, increases in call volume have been noted to the national Spanish-language quitline portal, 1-855-DÉJELO-YA, during Tips Spanish promotions, suggesting that Spanish-language tobacco education media campaigns may be effective in motivating Spanish-speaking people who smoke to seek help from a Spanish-language quitline (Zhang et al. 2018).

The findings from the Tips campaign contribute to the evidence base of interventions designed to increase awareness of, access to, and utilization of cessation services. These findings provide evidence that broad-based national media campaigns, if designed and delivered with careful attention to addressing populations affected by tobacco-related health disparities with sufficient dose and duration as well as ad placement strategies that are focused on reaching population groups affected by tobacco-related disparities, may contribute to reducing such disparities by influencing smoking cessation behaviors, including quit attempts and other quit-seeking behaviors.

Every Try Counts. FDA’s first smoking cessation campaign, Every Try Counts, ran from January 2018 to April 2020. Understanding that multiple quit attempts are often required to achieve long-term cessation (USDHHS 2014), the campaign underscored the health benefits of quitting and used positive messaging to increase motivation to quit among adults who had previously attempted to quit smoking unsuccessfully. The campaign was active in 35 U.S. counties with high prevalence of adult smoking. Messages were delivered through geotargeted digital, radio, and outdoor print advertisements. Each ad included a call to action to drive people who smoke to the campaign website, which was developed in partnership with NCI and which features quitting tips; chat-based counseling on cessation; and links to phone-, text messaging-, and app-based cessation interventions.

In early 2020, Every Try Counts shifted to a national digital campaign to reach a broader audience. During the time the campaign was in market, Every Try Counts had more than 769 million digital views and sent more than 1.6 million unique visitors to EveryTryCounts.gov, prompting more than 15,000 sign-ups for a text messaging-based cessation program (FDA n.d.a).

##### Media Campaigns Designed to Reach Population Groups of Specific Races or Ethnicities

This section briefly highlights the evidence regarding campaigns focusing specifically on racial and ethnic population groups, including evidence published after 2014, but does not repeat the systematic review of the literature found in NCI Tobacco Control Monograph 22. Chapter 5 of the 1998 Surgeon General’s report concluded that interventions addressing tobacco-related health disparities in racial and ethnic groups should reflect the focus population’s cultural values and psychosocial correlates of tobacco use, be language appropriate, and use strategies that are acceptable and credible to members of the group (USDHHS 1998).

A 2017 Cochrane review suggested that the incremental benefits of behavior change-oriented mass media campaigns intended to reach people of a single race or ethnicity were limited compared with nontargeted campaigns, concluding that “the available evidence is inadequate for understanding whether mass media interventions targeted toward ethnic minority populations are more effective in changing health behaviors than mass media interventions intended for the population at large” (Mosdol et al. 2017, p. 2). However, this review included only randomized trials and interrupted time series, examined other conditions besides smoking, and identified only six trials that met the eligibility criteria through 2016, of which four were smoking related. One of the four smoking-related trials assessed the use of a generic booklet versus a tailored booklet, and trial sizes were small in the others.

Several tobacco countermarketing campaigns have focused on different racial or ethnic groups and were either designed specifically for a priority population or as tailored components of a campaign designed for the general population; tailoring strategies in such campaigns have included language adaptation (e.g., California’s 2018 Flavors Hook Kids campaign appeared in seven languages), cultural adaptation, or both.

One community cluster randomized trial of mass media campaigns that included messages developed for African American and Hispanic youth found no significant effect on smoking among youth overall, although some changes in attitudes among Hispanic youth were observed (Flynn et al. 2010). However, the authors noted that this trial occurred in a relatively strong tobacco control environment with other nonexperimental community interventions occurring contemporaneously, including a substantial national media campaign that would have been viewed by both controls and intervention participants at higher exposure levels than the experiment provided, thus diminishing their ability to detect an effect (Flynn et al. 2010).

Analyses of comparative effects for specific racial and ethnic groups within more recent large media campaigns intended to reach all people who smoke—but with attention to salience, motivation, and media placement for key health disparity focus populations—have found strong evidence of benefit in all priority populations, especially for African American people (reviewed in detail elsewhere in this section) (Vallone et al. 2011b; Davis et al. 2017; McAfee et al. 2017).

It is also possible that media campaigns may be necessary, but not sufficient in themselves, to reach priority populations. In a study reviewing the effect of media campaigns on socioeconomically disadvantaged populations, Niederdeppe and colleagues (2008) suggested that, to increase efficacy, general campaigns should be combined with other programs (e.g., school-based interventions, state programs) to better influence priority populations. A later study in Boston, which compared mass media strategies for referring Black and Hispanic people who smoke to the Massachusetts quitline, found that a large-scale media campaign resulted in more provider referrals based in community health centers (pediatric and dental clinics) for Black and Hispanic people who smoke compared with self-referral to the quitline based on campaign exposure (Russo et al. 2018).

##### Media Campaigns Designed to Reach People with Mental Health Conditions

People with mental health conditions are more likely than those without such conditions to smoke cigarettes; in 2021, 28.1% of adults experiencing serious psychological distress (vs. 10.9% of those who were not experiencing such distress) reported smoking cigarettes (Cornelius et al. 2023a). Few campaigns have been directed specifically at this population. In 2016, the Tips From Former Smokers campaign designed and aired an ad specifically to motivate quit attempts among people who smoked and were living with anxiety or depression (Prochaska et al. 2019). The ad was developed in consultation with mental health and tobacco treatment experts. Evaluation of this ad’s effect using a pre–post longitudinal survey demonstrated that adults with a mental health condition who reported exposure to the ad (vs. no exposure) were more likely to report a quit attempt when controlling for overall campaign exposure (aOR = 1.25; 95% CI, 1.03–1.52). Exposure to this ad was not associated with trying to quit smoking among adults without a mental health condition (aOR = 0.97; 95% CI, 0.83–1.14). Exposure to other Tips ads was associated with quit attempts among adults without a mental health condition (aOR = 1.19; 95% CI, 1.02–1.40) (Prochaska et al. 2019).

In an earlier randomized Tips dosing trial without tailored ads, McAfee and colleagues (2017) found that people with mental health conditions who were receiving standard dosing exposure to the campaign were more likely to make a quit attempt than those without a mental health condition (42.5% vs. 32.0%; p <0.01), but increased dose exposure did not increase quit attempts (39.5% vs. 42.5%; p = 0.79).

#### Additional Design, Delivery, and Evaluation Considerations

One advantage of using targeted communication to address tobacco-related health disparities is that this approach focuses on audience characteristics when designing and delivering the message, which can improve audience engagement with the message and, in turn, can improve acceptance of the message (see Chapter 5 in USDHHS 1998) (Kim et al. 2016b). However, limited resources often present a challenge to programs’ capacity to develop, pretest, deliver, evaluate, and sustain separate ad campaigns for each potential priority focus population (USDHHS 2012; CDC n.d.c). Furthermore, consideration of intersectional identities may add to the complexity of campaign development. Some campaigns have approached these challenges by developing a comprehensive, integrated approach to include a broad-based campaign with ads that are carefully designed with focus population representation in ad content, ads tested to appeal to multiple focus populations, and ad placement strategies that ensure exposure by focus populations as well as the overall population of people who smoke.

This integrated approach is sometimes supplemented with additional ads that focus on specific health disparity messages, focus populations (including both language-specific and culture-specific ads), and more specialized delivery channels (NCI 2017b). The components of a successful campaign include effective message design, pretesting including with focus populations, delivery channels that are appropriate and widely used by focus audiences, sufficient duration and funding, and process and outcome evaluation (CDC 2014; Baig et al. 2017; Hair et al. 2017; McAfee et al. 2017; Sanders et al. 2018).

##### Message Design

Health interventions and media campaigns should consider designing messages to meet the literacy, language, cultural, and motivational needs of various populations (Resnicow et al. 2002; Liu et al. 2013). Media campaigns intended to reach diverse ethnic groups are encouraged to translate their messages into multiple languages, as seen in California’s Flavors Hook Kids campaign, Asian-language adult campaigns, and Tips Spanish-language ads. Rather than simply translating messages into different languages, however, these and other campaigns, such as FDA’s Fresh Empire campaign, also incorporate cultural values into the messages that are relevant to the intended audience. For example, the Asian Tobacco Education, Cancer Awareness, and Research’s (ATECAR’s) media campaigns (Ma et al. 2004) focused on Chinese, Korean, Vietnamese, and Cambodian American population groups, who have disproportionately high rates of smoking among men (but not women) compared with the national average smoking rate across race and ethnicity. ATECAR’s newspaper columns and 30-minute radio programs (which ran in 2001 and 2002 in Philadelphia and neighboring areas) were composed in the four relevant languages (Chinese, Korean, Vietnamese, and Cambodian) and acknowledged the highly favorable social norms toward smoking in Asian cultures with the intent of effectively approaching Asian American people who smoke and changing their norms, perceptions, and behaviors around tobacco use. Although a formal, large-scale evaluation was not conducted, ATECAR’s campaigns were received favorably among the intended audience, who gave the content high ratings for its helpfulness with quitting smoking.

Using tailored format features that are appropriate for and preferred by the intended audience is also an important strategy for engaging priority populations in smoking prevention and cessation campaigns. Both the Truth and The Real Cost campaigns sought to reach at-risk youth populations by designing messages to appeal to the audience’s sensation-seeking tendencies, through both execution styles (such as graphic images, special visual effects, fast-paced edits) and content (such as shocking, relevant narratives). The use of narratives that shock or otherwise engage the audience and intense format features in countermarketing media campaigns was found to increase recall among youth audiences (Allen et al. 2015). Similar messaging strategies should continue to be evaluated to determine whether specific execution styles and thematic content styles, that resonate with priority populations, influence tobacco-free behavior among these populations.

In addition, tobacco countermarketing advertisements that had emotional personal testimonials about the consequences of smoking or graphic images depicting the negative health consequences of smoking were found to have greater recall and perceived effectiveness among adults who smoke compared with advertisements without these types of content (Niederdeppe et al. 2011). Moreover, these advertisements were found to be more effective in motivating quit attempts by lower income adults who smoke and who have lower levels of education compared with advertisements without testimonials or graphics (Garrett et al. 2015).

Featuring people who are relatable to the target audience in tobacco countermarketing messages may be an effective strategy to increase the audience’s engagement with the messages. For example, campaigns that target specific populations—such as Black, Hispanic or Latino, or minoritized sexual and gender identity groups—were more likely to be supported by the in-group members who shared the social identity than by members of other social identities (Baig et al. 2017). In addition, having actors dressed in styles that were similar to those of the audience members was shown to increase smokefree attitudes, increase the effectiveness of smokefree messages, and lower susceptibility to smoking among the adolescents who saw those messages (Moran and Sussman 2014, 2015). Tobacco control public service announcements featuring characters who smoked and had demographic similarities to members of the target audience were also shown to increase the audience’s engagement with the message, which, in turn, increased the perceived effectiveness of the message (Kim et al. 2016b).

Other studies have demonstrated different engagement factors. In a study of perceived and actual effects on quit behavior in the Tips campaign (Davis et al. 2017), study participants were asked about the perceived effectiveness of ads before they were run and then months later after exposure to the full campaign. Higher perceived effectiveness scores for an ad were more predictive of increased quit attempts than concordance between the race or ethnicity of the study participant and that of the ad participant. The authors concluded that message characteristics (such as graphic or otherwise engaging visuals and emotional content) may play a more important role in perceived effectiveness than the race or ethnicity of ad participants.

Conducting formative research to understand the key beliefs and preferences of focus audiences is a critical strategy for tobacco prevention and control campaigns (Atkin and Freimuth 2001; CDC 2014; Davis et al. 2017). For example, when conceiving The Real Cost campaign, FDA worked with marketing groups that conducted formative qualitative research with adolescents to inform the development of the campaign brand and campaign advertisements (Duke et al. 2015a) and quantitative research to examine adolescents’ beliefs about tobacco use, which identified the consequences of smoking, social acceptance, and social popularity as salient themes that resonated with youth (Brennan et al. 2017). Based on this formative work, FDA used messages about the cosmetic and health effects of smoking and addiction-related loss of control.

Similarly, formative focus group research for the development of NCI’s Smokefree Teen website found that teens attributed their own smoking to stress from their home life, friends, and school. Therefore, website messages highlighted the reasons why young people smoke and challenged the misperception that smoking could alleviate these issues. Campaigns that use a peer-crowd approach are designed to resonate with the values of these groups, such as independence and control (Fresh Empire) or self-expression and inclusion (This Free Life).

Finally, focus group interviews with key informants are an important step in developing culturally appropriate tobacco prevention and control messages for underserved and high-risk populations, including people living in rural communities (Riker et al. 2015). In summary, using a comprehensive process that fully assesses knowledge, attitudes, behaviors, and beliefs about smoking related to culture should be a formative part of message design in future mass media campaigns that target population-level tobacco prevention and cessation outcomes.

##### Delivery Channels

Diverse delivery channels are used in health campaigns to reach and engage target audiences through multiple platforms. The most successful campaigns have historically used a mix of mass media channels—usually with television and radio predominating for adults because of their high reach and proven impact, supplemented with social and digital media, which are channels used by many key populations. Youth campaigns may reverse this channel prioritization. Delivery channels may also include school curricula (for youth); various sections of a newspaper; earned media announcements on the radio and television; posters; the Internet; out-of-home ads such as those on billboards, buses, and buildings; movies; cartoons; music videos; online streaming and on-demand media; testimonials; social media (such as Instagram, TikTok); brand ambassadors; and local outreach events. Furthermore, newer media placement purchasing algorithms now allow for more precise tailoring of delivery based on audience characteristics (Singh 2020). However, because the delivery channel media environment—especially for youth and young adults—is continuously and rapidly evolving, it is important that media campaigns ensure that they have up-to-date knowledge and/or engage media placement firms that are tracking viewing trends in target populations.

Several examples exist for the successful use of targeted delivery channels to reach focus audiences. For example, messages from the Truth campaign were strategically placed on television during programs with high teen viewership and that were particularly attractive to sensation-seeking youth (Duke et al. 2009). Using a dissemination strategy that reflects the culture of the focus audience has been a cost-effective method for achieving substantial exposure for the Truth campaign as well as for social media engagement in general and for population-level health improvement (Hair et al. 2017). Another example of using a dissemination strategy reflective of the culture of the focus audience is CDC’s Tips campaign; in addition to translating ads into Spanish and having Hispanic or Latino ad participants featured in the campaign, the campaign worked with Spanish-language stations to develop earned media segments, which led to increased reach (Zhang et al. 2018; Dilley et al. 2020).

Use of digital channels is critical when trying to reach many priority populations, particularly given the high levels of smartphone ownership among Black and Hispanic people of all income levels (Atske and Perrin 2021). Several campaigns have incorporated digital approaches into their dissemination strategies. For example, the Smokefree Teen promotion campaign actively used social media channels to reach adolescents, as past research suggested that teens spend more time using their cell phones or computers to access social media rather than using traditional media, such as broadcast network television (Sanders et al. 2018). Messages for the Smokefree Teen promotion campaign were placed on online platforms that provide video, music, and social networking services, such as Facebook, Twitter, YouTube, Hulu, Pandora, Spotify, and the CW network. Smokefree Teen online marketing campaigns turned out to be more cost-effective in increasing engagement with text message services than traditional media campaigns (Sanders et al. 2018).

Similarly, The Real Cost campaign leveraged a variety of communication channels, including television, online videos, social media, media partnerships with youth-focused content, posters for schools, and a campaign website (Duke et al. 2019; Zeller 2019). In addition, FDA’s Fresh Empire and This Free Life campaigns used digital marketing tactics and innovative approaches with social media and influencers, interactive websites (such as games and quizzes), and local events (Guillory et al. 2020; Crankshaw et al. 2022).

The use of social media platforms by such campaigns represents a rapidly emerging strategy and area for research. A review by Chan and colleagues (2020) examined evaluation measures of tobacco control campaigns using traditional and digital media platforms for 17 campaigns. The review included evaluations reported in 51 peer-reviewed articles, 17 marketing reports, and 4 gray literature evaluation reports and focused largely on behavior change outcomes. Evaluation measures commonly assessed engagement (e.g., number of website visits) with other measures, including engagement on social media, changes in attitudes, and number of people initiating contact for smoking cessation services. However, few evaluations included measures of media platform attribution (i.e., where participants saw the campaign). This review highlighted the need for guidance about selecting digital media-related metrics for campaign evaluations. Moreover, case studies of digital segmentation efforts in the nonprofit, government, and academic sectors have indicated that such segmentation increases the reach and frequency of messages delivered to targeted populations and, as a result, may enhance future public health campaigns (Evans et al. 2019).

Using influencers to spread tobacco prevention and control messages is another strategy that goes beyond traditional mass media to disseminate health messages to focus audiences. For example, the HAVOC (Fallin et al. 2015a) and Commune (Commune n.d.) social branding campaigns hired influential community members from the young adult target audience as brand ambassadors, which was effective in maximizing the outreach of each campaign. Working with social media influencers could be particularly relevant to populations facing tobacco-related health disparities by identifying members of these communities to serve as influencers (Fallin et al. 2015b). Campaigns should, however, be aware that attempting to enter financial relationships with social media influencers or brand ambassadors may add a less controllable element into the campaign mix and potentially pose particular challenges for government-sponsored campaigns.

Any existing gaps in media access, including digital channels, such as in rural areas and among people of lower SES (Vallone et al. 2015), have narrowed substantially in part due to almost universal access to cell phones in the United States (Pew Research Center 2021) and increasing access to broadband Internet, although some gaps in broadband access remain (Federal Communications Commission 2021). For example, data from 2019 indicated that most rural residents had smartphones (71%) and home Internet access (63%) (Perrin 2019) and 85% of rural residents used the Internet, 68% of whom used it to obtain health information (Harvard T.H. Chan School of Public Health 2019). The vast majority of rural residents view technology as vital to compensate for sparse or absent community resources, limited access to healthcare professionals, and to avoid the need for long-distance travel (Perrin 2019). Thus, digital health resources are increasingly relevant to the rural population. It is important to assess which dissemination channels are both popular and likely to be accessible by priority populations experiencing tobacco-related health disparities. Chapter 5 provides additional detail on access to media and the Internet among different population groups.

In summary, digital campaigns are an emerging area that warrants further evaluation and offers potentially cost-effective ways to reach priority populations, particularly among youth. Ultimately, evaluation and research methodologies that allow for reliable estimates of the impact of digital campaigns on quit attempts and quit success, including among population groups affected by tobacco-related disparities, are needed.

##### Evaluation Considerations

Media campaigns may have practical and political considerations and limitations that may make it difficult to evaluate certain aspects of these campaigns both for the overall population and among priority populations experiencing tobacco-related health disparities. For example, publicly funded campaigns may be limited ethically and politically in their capacity to include a control condition that receives no exposure to a media campaign. Thus, comparison often relies on time series or geographically similar groups or recall of campaign exposure, which is subject to confounding and bias. There have been a few large, randomized trials of large media campaigns in which, for example, the dose of the media buy is varied randomly by ad market (Flynn et al. 2010; McAfee et al. 2017). Some time series trials have gone to great lengths to overcome potential environmental biases, such as other tobacco control variables or seasonal variations. For example, a campaign conducted in the spring of a year may examine pre-, post-, and the previous year’s outcomes to minimize nonintervention-related temporal trends. Alternatively, media “doses” can be delivered in discrete, brief, and repeated pulses separated by no media exposure, with tracking of a meaningful outcome that can be reliably measured on a daily or weekly basis. For example, CDC’s Tips campaign has delivered national ad buys tagged with a call to action to call 1-800-QUIT-NOW (the national quitline portal); these ads were turned off and on weekly or biweekly, with calls to quitlines roughly doubling during the weeks when the campaign was on air (CDC 2013). Quitline call volume and caller demographic characteristics have also been correlated with changes in ad buy intensity or content (Zhang et al. 2015a; McAfee et al. 2017; Davis et al. 2018).

Some media campaigns have developed synergistic relationships with state-based quitlines, which can benefit quitline reach, media message engagement, and campaign evaluation. This symbiosis has included quitline reliance on campaigns to increase quitline calls, particularly among focus populations such as people who are uninsured or enrolled in Medicaid (Zhang et al. 2015a). In turn, many characteristics make quitlines a valuable tool for evaluating the effect of media campaigns on cessation behaviors, including among priority populations:

- Quitlines collect a uniform set of sociodemographic and behavior-related data elements for all callers receiving services (known as the “minimal dataset”) (North American Quitline Consortium n.d.b).
- Quitlines routinely collect intermediate behavioral metrics (e.g., calls to quitlines, program enrollment and participation) that can be correlated with media buys, potentially to the level of specific ads.
- Quitlines collect metrics examining satisfaction and quit outcomes on subsets of callers.
- Funding levels and media characteristics have varied over time and between states; quitline utilization is correlated to both funding and media promotion.

One health equity question regarding media campaigns is whether they selectively influence quit behaviors in some groups of people who smoke more than in others, thereby either increasing or decreasing health disparities in successful quitting. Thus, studies evaluating the effectiveness of such campaigns in diverse population groups must be sufficiently powered to detect such differences. This question has been examined using population-based surveys, but because demographic information on state quitline callers is collected routinely, the impact of media campaigns on specific focus populations has also been examined by observing caller characteristics before, during, and after campaigns. In general, calls from priority populations have either remained proportional, or in some instances increased, during campaigns, such as increases in uninsured callers observed during the first year of the Tips campaign (Zhang et al. 2015a) and increases in Medi-Cal callers and engagement during California targeted campaigns, particularly among African American and English-speaking Latinx population groups (Vijayaraghavan et al. 2018b). Media campaigns remain a critical component of comprehensive tobacco control programs for the general population and for reaching priority populations.

#### Summary and Recommendations

As outlined in the 2014 and 2020 Surgeon General’s reports, NCI Tobacco Control Monograph 22, and the evidence reviewed in this chapter, the efficacy of media campaigns has been demonstrated in a diversity of population groups. Tobacco countermarketing mass media campaigns are known to prevent initiation of tobacco use, increase calls to quitlines, increase smoking cessation, and reduce the prevalence of tobacco use among adults and youth (USDHHS 2014, 2020; NCI 2017b). However, it remains unclear whether media campaigns aimed at a specific focus population are more effective at decreasing disparities in tobacco initiation, use, and cessation (including use of cessation services) than broader campaigns designed to resonate with multiple focus populations.

The evidence base regarding the impact of countermarketing campaigns on several focus populations has increased in recent years, including among minoritized racial and ethnic groups, sexual orientation and gender identity groups, groups with lower SES, and those with mental health conditions. Evidence reviewed in this section highlights the potential benefits of designing, developing, and delivering media campaigns that focus on, or are developed to reach, priority populations.

The recommendations made here are relevant within the context of both broad-based and priority population-specific campaigns. Careful attention should be paid during message development to ensure that campaign messages resonate with the specific population(s) a campaign aims to influence; group characteristics to keep in mind during message development include sociodemographic factors, tobacco products used, quitting interest, psychographics (e.g., cultural values), preference for media channels, literacy needs, language preferences, and intersectionality of multiple factors.

Supplemental media efforts may also be added to general market campaigns to (1) increase campaign reach as well as integration with rural communities, school interventions, community programs, and other social support networks; and (2) influence policy changes that might enhance the effect of these campaigns on priority populations (Niederdeppe et al. 2008; Durkin et al. 2012; NCI 2017b). Given that demographic characteristics may inform how media channels are accessed (e.g., adolescents tend to use different social media applications than adults), further evaluation studies are warranted to inform how best to enhance the reach and effectiveness of targeted and general tobacco countermarketing campaigns.

Beyond programmatic recommendations, specific areas that may benefit from further investigation to reduce tobacco-related health disparities include studies to examine

- How different campaign approaches (designed and delivered to maximize impact for multiple groups or to primarily influence a specific population group) compare in their effects on both specific populations and the overall population;
- How different components of media campaigns (message content, framing, targeting, duration, dose, channels) affect the campaign’s effectiveness;
- How to maximize the reach and effectiveness of media campaigns for population groups with a primary language other than the dominant language;
- Use of controlled time series, sequential randomized trials, and pilot RCTs, when feasible, to evaluate targeted and broad-based media campaigns before the widespread dissemination of such cessation campaigns among priority populations, as recommended by Guillaumier and colleagues (2012); such studies should be sufficiently powered to detect differences among population groups of interest;
- How to maximize the reach and effectiveness of general and focused media campaigns among specific understudied population groups, particularly the LGBTQI+ community, American Indian and Alaska Native population groups, Native Hawaiian and Pacific Islander population groups, older adults who smoke, those with mental health conditions, and rural population groups;
- Whether different framing and tones are perceived as more effective by different focus populations (e.g., negative vs. positive gain framing, internal vs. external motivation);
- Trends in patterns of media use within different focus populations, including continued use of broadcast media as well as shifts to digital and social media;
- Approaches to digital and social media marketing that can help address, and not exacerbate, disparities in tobacco use;
- How general media market campaigns that bolster support for equitable tobacco control policies, such as those related to flavors and menthol, affect tobacco-related health disparities;
- How media countermarketing can help reduce the impact of new tobacco industry campaigns that attempt to renormalize tobacco use behavior and influence the public health policy environment (see Chapter 5); and
- The effect of media campaigns on the use of noncigarette tobacco products, including whether campaigns designed to reduce smoking or vaping have the intended effects on use and perceptions of all tobacco products equally or differentially.

Mass media campaigns should be developed to meet the literacy, language, cultural, and other needs of priority populations. Their development may benefit from the following:

- The use of community-engaged research approaches to optimize the understanding of the needs of priority populations;
- Formative testing and post-deployment evaluation, especially for new campaign ads, strategies, materials, media channels, and resources;
- The use of appropriate media channels that are used by priority populations;
- The inclusion of linkages to barrier-free, evidence-based cessation support resources; and
- Deployment to support policies and programs that promote health equity in addition to supporting tobacco cessation efforts by individual people.

Finally, to achieve equity and eliminate tobacco-related health disparities, media campaigns should be integrated with multicomponent, comprehensive, well-funded, and sustainable tobacco control programs, with ongoing evaluation of impact (CDC 2015). It is critical that, regardless of whether a campaign is aimed at a single focus population or a broader audience of people who use tobacco, extra steps be taken to ensure that campaign evaluations have sufficient capacity to examine the impact among population groups experiencing health disparities. This may, for example, require oversampling of focus populations, careful attention to sample recruitment and retention methods, and community-engaged research approaches.

The evidence reviewed in this section is sufficient to infer that mass media countermarketing campaigns are effective at increasing quit attempts among many population groups that are impacted by tobacco-related disparities, particularly when designed and delivered with attention to reach and relevance to these population groups. Mass media campaigns should be well funded and of sufficient ongoing duration and dose to create meaningful population-level decreases in tobacco use initiation and prevalence, including among population groups affected by tobacco-related disparities. Ultimately, implementing these recommendations for mass media campaigns focused on tobacco prevention or cessation has the capacity, when combined with other tobacco control strategies, to improve health outcomes in population groups suffering from tobacco-related health disparities.

## Organizational-Level Programs and Interventions

Opportunities exist to address tobacco-related health disparities at multiple levels, including by implementing interventions, policies, and practices within organizational and institutional settings. This section focuses on interventions in environments where people learn, seek healthcare, and work, but does not summarize all possible organizational programs or interventions that could potentially reduce tobacco-related health disparities. This should not preclude tobacco control practitioners from taking action to pursue interventions in other settings and to evaluate and report on the results of those activities.

### School-Based Tobacco Prevention Programs

Youth and young adults are disproportionately affected by tobacco product marketing and have disproportionately high tobacco use prevalence. This is problematic not only because of the dangers of nicotine for the developing brain, but also because most adults began using tobacco products when they were adolescents (USDHHS 2012, 2014, 2020). Disparities in tobacco product use among youth of different population groups can lead to disparities in use among adults. Health promotion efforts intended to reach youth are often centered in schools, which are a promising venue for preventive efforts because youth spend many of their waking hours in school and because schools are a major socializing institution for youth (Trickett and Moos 1973; Comer 1988; Flay and Collins 2005; NCI and WHO 2016). School-based interventions for tobacco prevention and cessation are particularly appealing because they leverage an existing institutional setting with broad reach to youth (Wiehe et al. 2005). School-based programs may be helpful in reaching youth who do not receive tobacco prevention and treatment information from other sources (NCI and WHO 2016).

The evidence on school-based programs to prevent and reduce youth tobacco use is mixed. However, programs “with evidence of effectiveness, containing specific components, can produce at least short-term effects and reduce the prevalence of tobacco use among school-aged youth” (USDHHS 2012, p. 10). School-based programs will be most effective when combined with a comprehensive approach that also addresses more distal, social, and community influences (USDHHS 2012). In a critical review of reviews of school-based smoking prevention programs, Flay (2009a) found suggestive evidence of long-term effectiveness in terms of reducing tobacco use among youth if programs (a) included interactive exercises that emphasized the social influences of tobacco use or learning refusal skills; (b) offered 15 or more sessions with the same group of youth; and (c) targeted participation starting in middle school, with at least some exposure to tobacco prevention materials in ninth grade.

#### Key Practices for School-Based Programs to Prevent Tobacco Use Among Youth

The 2012 Surgeon General’s report recommended that school-based programs “should be comprehensive, interactive, start early, be sustained, incorporate an appropriate amount of lessons, and be integrated into a community-wide approach” (USDHHS 2012, p. 792). Effective curricula should employ the existing key practices for school-based prevention curricula and address the main reasons why youth find tobacco products appealing, especially emerging tobacco products. Reviews, meta-analyses, and the broad literature about school-based tobacco prevention programs show that successful programs:

- Are based on the social influences approach (i.e., educating youth about social norms and social influences and providing skills for resisting peer and media influences and tobacco product marketing);
- Involve interactive learning strategies that include discussions about social norms and building refusal skills; and
- Rely on theories of positive youth development, including using same- or similar-age peers as leaders or facilitators (Wiehe et al. 2005; Flay 2009a,b; USDHHS 2012; Thomas et al. 2013, 2015; Bonell et al. 2016; Harvey et al. 2016).

Social influence theory is a part of the social influences approach, which highlights the importance of educating youth about social norms and provides them with skills for resisting the influence of their peers and others. That approach also involves behavioral theories, which assert that decisions to use tobacco products are shaped by perceptions of tobacco-related risk and benefit and perceived acceptability of the tobacco product, which in turn can be shaped by both public health educational campaigns and tobacco product marketing (Ajzen 1985; Catalano et al. 2004; Song et al. 2009). Components of school-based programs that have focused on combustible and smokeless tobacco use also show promise for addressing e-cigarette use (Kelder et al. 2020).

Positive youth development is an approach that allows educators to work with youth in a way that provides support and opportunities to learn about the larger process of development, mainly the cognitive development that occurs during adolescence as youth make life decisions (Bonell et al. 2016). The positive youth development approach includes learning in the classroom setting, but it also incorporates community involvement to provide the proper resources to help guide youth through their critical journey to young adulthood. The positive youth development approach can be implemented through promoting positive relationships with family and friends, encouraging youth to be leaders or to participate in activities that interest them, providing youth with adult mentorship, and ultimately providing a safe environment in which youth can focus on personal development (Bonell et al. 2016). Programs involving a youth development framework typically share components, such as the following:

- Increase participants’ exposure to supportive and empowering environments that include positive relationships with peers, parents, and other adults;
- Engage youth in activities and opportunities for a range of skill-building and perspective-broadening experiences;
- Encourage youth involvement, empowerment, and leadership; and
- Encourage peer involvement, which tends to have more frequent and intense interactions compared with adult interactions; peers are powerful influences on a child’s development of identity and autonomy (Leffert et al. 1998; Roth and Brooks-Gunn 2003; Mannes 2006; Ramirez et al. 2006; Morton and Montgomery 2011; Lowry et al. 2017; National Institute for Health Care and Excellence 2022a, b).

Tobacco prevention curricula also should educate youth on factors that influence their susceptibility to initiating tobacco use, such as marketing, flavors, social pressures, and perceptions of harm regarding different products. In terms of marketing, manufacturers and retailers of tobacco products aggressively market to youth through the Internet, social media, television, radio, event sponsorship, celebrity placement, and strategic positioning in convenience stores, often next to candy products (Cobb et al. 2013; de Andrade et al. 2013; Grana et al. 2013; Mantey et al. 2016; Singh et al. 2016a,b,c; Hammig et al. 2017; Marynak et al. 2018a). As discussed earlier, tobacco products often contain flavorings (candy, fruit, menthol, mint, and others) that make them particularly appealing to youth (see Chapters 3 and 5) (Grana et al. 2013).

Moreover, adolescents generally lack knowledge about tobacco products and harbor misperceptions about their harm (Trumbo and Harper 2013; Ambrose et al. 2014; Akl et al. 2015; Anand et al. 2015; Roditis and Halpern-Felsher 2015; Amrock et al. 2016; Roditis et al. 2016a,b; Dobbs et al. 2017; Giovacchini et al. 2017; Huang et al. 2017a; Kowitt et al. 2017; McKeganey et al. 2018; Zare et al. 2018; Goldenson et al. 2019; Chen-Sankey et al. 2021; Gentzke et al. 2022). Knowledge gaps and misperceptions may be particularly prevalent among some population groups, owing to communication barriers (Cowgill et al. 2020).

The strategies listed earlier are key practices for school-based prevention programs that can help address tobacco use among youth generally. Little research has been done to assess whether these strategies, if implemented comprehensively, can help reduce disparities in tobacco use among youth or whether any specific elements of these programs are particularly effective at or can be enhanced to help reduce disparities in tobacco use. Public health departments and education departments in some states, like California, have collaborated to implement youth-engaged tobacco prevention programs to address tobacco-related disparities (California Department of Education n.d.). Evaluation studies regarding these types of programs would help inform efforts elsewhere.

The tobacco industry has also sponsored tobacco prevention curricula, but historically these curricula have been shown to serve as additional indirect marketing strategies and strategies implemented to avoid regulation and legal liability (USDHHS 2012; NCI and WHO 2016). Such curricula should not be considered to be effective or evidence-based prevention or cessation curricula (NCI and WHO 2016; WHO 2018). Studies of tobacco industry documents have found that tobacco industry curricula (a) failed to portray the true detrimental harm of their products to youth and (b) subtly promoted smoking to maintain a youth audience (Landman et al. 2002). Industry-sponsored curricula also failed to follow the best practices for addressing the targeted marketing and building skills needed to resist the industry’s advertising efforts (Landman et al. 2002). These same practices have been implemented by e-cigarette companies, such as JUUL Labs’ attempts to implement school-based e-cigarette prevention curricula (Liu and Halpern-Felsher 2018).

Most young people who use tobacco products want to quit (Gentzke et al. 2022). School-based tobacco prevention and cessation programs can be bolstered by well-implemented policies prohibiting tobacco use in schools (Galanti et al. 2014; Cole et al. 2019). Traditional disciplinary measures used to enforce violations of school policies, such as suspension for students caught using a tobacco product on campus, are unlikely to help students quit tobacco use and could permanently impact their academic and future prospects (CDC n.d.). Such actions could also exacerbate socioeconomic disparities as suspensions disproportionately affect students of color, students from families with lower incomes, LGBTQI+ students, male students, and those receiving services for special education (Leung-Gagné et al. 2022; CDC n.d.). Tobacco-free school policies that focus on educating, rather than penalizing, youth who violate tobacco-free school campus policies can help bolster efforts to reduce tobacco use prevalence and advance equity (Public Health Law Center 2019b; American Lung Association 2022). Additionally, given that some school-aged youth already use tobacco products, school-based prevention programs that include a cessation component, including resources for quitting use of e-cigarettes, could increase program impact for all students. Cessation components of programs can also be utilized for tobacco-free school policies that adopt a non-punitive approach to enforcement to help support educational success among vulnerable youth.

Given the changing landscape of tobacco product availability, marketing and use, it is important that developers of school-based tobacco prevention and cessation programs update, evaluate, and adapt their curricula to include evidence-based best practices, include content on emerging tobacco products, and be technologically savvy and integrated with platforms that resonate with youth (Baskerville et al. 2015b). Developers should continue to monitor the effectiveness of efforts to change perceptions about tobacco products and patterns of tobacco use among youth, including among population groups that experience tobacco-related health disparities.

### Interventions and Policies in College-Based Settings

In the fall of 2019, a large majority of undergraduate students at 4-year public institutions (90%), private nonprofit institutions (86%), and 2-year public institutions (80%) were under the age of 25 (National Center for Education Statistics 2022)—a critical age given that nearly 1 out of every 10 people who smoke start between the ages of 18 and 25 (USDHHS 2012). In addition, some studies have shown that young adults who smoke often increase their cigarette use while in college (Bardus et al. 2020). Tobacco-free college campus policies are just one tool to address tobacco use among young adults, given that only 42.3% of U.S. young adults 18–24 years of age were enrolled in college or graduate school in 2021 (U.S. Census Bureau n.d.). These interventions can reduce tobacco use, create changes in social norms, and tend to have the support of students, which increases following policy implementation (Lupton and Townsend 2015; Bardus et al. 2020; Glasgow et al. 2021).

As with other adult population groups, disparities in tobacco use and exposure to secondhand tobacco smoke exist among college students. For example, data from the 2017 National Survey on Drug Use and Health showed that tobacco use was higher among college students with disabilities than among students without disabilities (Casseus et al. 2020). One study found that college students who were from minoritized racial and ethnic groups (including Black, Latino, and Asian study participants) and from rural areas had higher tobacco use than other students (Derefinko et al. 2018). The prevalence of tobacco use has been shown to be higher at community or technical colleges and at tribal colleges or universities than it is at 4-year colleges and universities (Berg et al. 2011, 2021c; Choi et al. 2016b; McIntosh et al. 2016). In addition, although exposure to secondhand tobacco smoke tends to be lower among people with more years of formal educational, one study (Pacheco et al. 2018) surveyed 1,256 American Indian college students from three tribal colleges in the Midwest and Northern Plains and found that nearly 60% reported being exposed to secondhand tobacco smoke during the preceding 7 days; 66% of those surveyed who did not smoke and 34% of those surveyed who smoked supported having a smokefree campus.

#### Tobacco-Free College Campus Policies

Young adults who attend 2-year colleges or have a 2-year college degree have higher rates of tobacco use, compared with those attending 4-year colleges or with a 4-year college degree, and those who do not attend college or do not have a college degree have the highest rates of tobacco use among people in this age group (Lenk et al. 2012; Odani et al. 2019; Schulenberg et al. 2021). Disparities in tobacco use on college campuses may be attributable in part to a wide variety of contextual factors, including the presence and strength of campus-based tobacco control policies (Venkataramani et al. 2019; Berg et al. 2021c).

Tobacco control programs that have been implemented at the state, territorial, tribal, and local levels to address multiple factors—such as policy, education, and cessation—have contributed to declines in the prevalence of tobacco use (CDC 2012c). The evidence base that these programs rely on can inform key practices for campus-based tobacco interventions, such as tobacco-free campus policies. For example, more than a decade ago, the American Nonsmokers’ Rights Foundation developed tools for the adoption of smokefree college campus policies based on its experience providing support for other smokefree policies throughout the United States (American Nonsmokers’ Rights Foundation 2009). Since then, the Foundation also developed tools for tobacco-free campus policies (American Nonsmokers’ Rights Foundation 2023b) that prohibit smoking and other tobacco product use. The American College Health Association (ACHA), in its Position Statement on Tobacco on College and University Campuses, incorporates many principles similar to those from the American Nonsmokers’ Rights Foundation when recommending that college campuses:

- Develop a strongly worded tobacco control policy that applies to all products and reflects best practices in tobacco prevention, cessation, and control, including barring relationships with the tobacco industry and prohibiting the sale of tobacco products;
- Distribute the policy widely and annually to inform all members of the campus community about the policy;
- Offer and promote initiatives in prevention and education that actively support a tobacco-free lifestyle and address the risks of all forms of tobacco use;
- Offer and promote programs and services that include practical, evidence- and theory-informed approaches to end tobacco use (such as screenings through health and counseling services, free or reduced-cost cessation counseling and medication options, including NRT, on campus);
- Advocate for requiring the inclusion of tobacco cessation medications and services in health insurance plans for students;
- Provide comprehensive marketing and signage to ensure that all college and university visitors, vendors, guests, and others are aware of the campus’s tobacco-free policy;
- Effectively implement, administer, and enforce all college and university tobacco-related policies, rules, regulations, and practices;
- Collaborate with local, state, and national public health entities to support and maintain a healthy tobacco-free environment; and
- Develop and maintain a campus-based tobacco task force to identify and address tobacco-related issues (ACHA 2012).

Policies such as this, which affect physical and social environments and provide cessation support, can reduce exposure to and use of tobacco (Blake et al. 2020; Berg et al. 2021c).

##### Prevalence and Characteristics of Tobacco-Free Campus Policies

The number of U.S. colleges and universities implementing comprehensive tobacco control policies doubled between 2012 and 2017 (Wang et al. 2018b). Of the more than 6,000 colleges and universities in the United States (National Center for Education Statistics n.d.), at least 2,599 had 100% smokefree campuses as of February 2022. Of these, 2,162 were also 100% tobacco-free, 2,233 prohibited e-cigarette use, 1,217 prohibited hookah use, and 571 prohibited smoking or vaping marijuana on school grounds (American Nonsmokers’ Rights Foundation 2023). A 2020 analysis found that 39.2%, 26.0%, and 20.0% of a sample of postsecondary educational institutions had enacted e-cigarette-free, hookah-free, and ACHA-recommended tobacco-free (all tobacco products including e-cigarettes and hookah) policies, respectively (Bayly et al. 2020). Elsewhere, a 2019 study estimated that, based on data from 2015 to 2017, 14.9 million college students (26.9%) and 8.9 million faculty and staff (25.4%) were protected by campus-based tobacco-free policies and state laws (Blake et al. 2020). Although the adoption of campus-based tobacco-free policies is on the rise, more attention is needed to address tobacco-related disparities among college students, including among minoritized racial and ethnic and sexual orientation and gender identity population groups, people of lower SES, and those from rural areas.

In addition to colleges and universities adopting their own tobacco-free policies, some colleges and universities are tobacco-free as the result of legislation. In the United States, as of February 2022, five states (Arkansas, Hawaii, Illinois, Iowa, and Louisiana) and one territory (the Northern Mariana Islands) required 100% smokefree campuses (all indoor and outdoor areas) for public postsecondary educational institutions (American Nonsmokers’ Rights Foundation 2023; CDC n.d.g). Of these, Iowa also required 100% smokefree campuses for private postsecondary educational institutions, and Hawaii and the Northern Mariana Islands required 100% tobacco-free campuses for public postsecondary educational institutions (American Nonsmokers’ Rights Foundation 2023; CDC n.d.g).

There were 32 fully accredited tribal colleges and universities in the United States in 2020 (U.S. Department of Education 2020). As of April, 2023, five tribal colleges spread across 18 campuses require their campuses to be 100% tobacco-free (all indoor and outdoor areas) (American Nonsmokers’ Rights Foundation 2023). Finally, Bayly and colleagues (2020) found that, compared with public postsecondary institutions, proprietary (privately owned, for-profit) institutions were less likely to have ACHA-recommended tobacco-free policies. Proprietary institutions have a higher percentage of students from minoritized racial and ethnic groups than public or private, nonprofit institutions (National Center for Education Statistics 2017; Bayly et al. 2020). Postsecondary educational institutions in the South and Midwest were more likely than those in the West to have enacted ACHA-recommended tobacco-free policies (Bayly et al. 2020). The student body at most 2-year colleges is more diverse compared with most 4-year colleges (National Center for Education Statistics 2022); thus, they provide a critical context for prevention and cessation interventions. However, 2-year institutions offer limited support for smoking cessation initiatives and efforts to prevent exposure to secondhand tobacco smoke (McIntosh et al. 2016). Differences in the adoption of tobacco-free college campus policies, based on setting, can be problematic in terms of tobacco-related disparities.

Continued adoption of tobacco-free campus policies, and especially in locations such as community or technical colleges, HBCUs, Hispanic- or Latino-serving institutions, and tribal colleges and universities can reach a diverse intersection of students, faculty, and staff; protect them from exposure to secondhand tobacco smoke; and reduce the social acceptability of tobacco use, thereby preventing initiation and promoting cessation (Wang et al. 2018b; Rath et al. 2019; Berg et al. 2021c).

In 2012, USDHHS launched the Tobacco-Free College Campus Initiative in partnership with the ACHA and the University of Michigan with the goal of encouraging the voluntary adoption of smokefree and tobacco-free campus policies across the United States (Blake et al. 2020). Truth Initiative has also supported the Tobacco-Free College Campus Initiative. In 2014, Truth Initiative—recognizing the lagging implementation of smokefree and tobacco-free policies in community colleges and HBCUs—developed its own programs and policies to provide grants and technical assistance to support the adoption of smokefree and tobacco-free policies in these educational settings (Rath et al. 2019; Blake et al. 2020). Since 2016, the CVS Health Foundation has partnered with the American Cancer Society, the Truth Initiative, and others to accelerate the adoption of tobacco-free campus policies, including at HBCUs, community colleges, and institutions that serve minoritized racial and ethnic groups (CVS Health 2019, Rath et al. 2019; Truth Initiative 2019a; Blake et al. 2020).

##### Impact of Tobacco-Free Campus Policies and Gaps in Tobacco-Free Campus Policy Research

Results from systematic reviews and meta-analyses have shown that tobacco-free campus policies reduce the prevalence of tobacco use, exposure to secondhand tobacco smoke, and protobacco attitudes among college students (Lupton and Townsend 2015; Bennett et al. 2017; Bardus et al. 2020; Berg et al. 2021c). Studies in other settings have also documented decreases in tobacco use after tobacco-free policies have been implemented (Fallin et al. 2015c; Wong et al. 2020; Wray et al. 2020). Other studies have shown that the presence of a campus tobacco-free policy may have other effects. For example, Barker and colleagues (2018) reported significantly lower odds of the presence of exterior tobacco marketing—specifically, e-cigarette advertising—at retailers near public university campuses with established tobacco-free policies compared to those without such policies. Additionally, using data from the American College Association National College Health Assessment study, Cannonier and colleagues (2019) reported improved academic performance among the general student population at a public university in a state with a high prevalence of smoking and the presence of a tobacco-free campus policy.

Although studies assessing the impact of tobacco-free campus policies included students who experience tobacco-related disparities, very little research has focused on how these policies, or specific aspects of these policies (such as capacity building, education, implementation, enforcement, tailored cessation programs) could help reduce tobacco-related disparities (Bardus et al. 2020; Berg et al. 2021c; Cuomo et al. 2021).

For example, challenges have been reported in the enforcement of tobacco-free college campus policies (Fallin et al. 2012; Russette et al. 2014; Braverman et al. 2018). Various measures to support implementation (Bresnahan et al. 2016) and enhance compliance have been found to be effective (Ickes et al. 2013, 2015); these measures include developing collaborations between state departments of health and college and university systems to effectively implement such policies (Bresnahan et al. 2016); developing tools to assess and improve compliance (Ickes et al. 2013, 2015); and developing communication materials and strategies (e.g., media campaigns) to strengthen tobacco control efforts (Mackert et al. 2019). Some studies suggest that population groups that use tobacco products at disproportionate rates may be more likely than other population groups to support these types of policies (Do et al. 2020; Martin et al. 2020), but that support may not be associated with changes in smoking behavior. These studies have not sufficiently explored possible differential intervention effects for specific population groups or for institutions serving students at tribal colleges or universities, community colleges, or HBCUs.

#### Summary and Recommendations

Current evidence indicates that tobacco-free campus policies lead to reduced tobacco use and exposure to secondhand tobacco smoke among college students. The evidence is insufficient to infer that tobacco-free policies on college campuses reduce tobacco-related disparities. However, continued adoption and evaluation of these policies is warranted, particularly in settings with a racially, ethnically, and/or socioeconomically diverse intersection of students, such as community colleges, tribal colleges and universities, and HBCUs. It is recommended that these policies comply with the ACHA’s tobacco-free policy guidelines, including that the policies be comprehensive and incorporate prevention and cessation programming.

Further examination of policies and policy development, implementation, and enforcement across different campus types is needed, as is research on the impact of these policies on different population groups on those campuses. Research that addresses tobacco use among different population groups on campuses is needed to inform broader policy decisions, including the promotion of and approach to providing campus-based cessation resources. Tools are available to increase engagement with and support for these policies among groups experiencing tobacco-related disparities (Newman Carroll et al. 2021). These tools can also improve enforcement of these policies. Continued development and assessment of these types of interventions to reach people experiencing disparities is important (Loureiro et al. 2021; Pulvers et al. 2022). Further, to maximize the reach of tobacco-free campus policies, additional policies that go beyond the scope of the ACHA’s guideline prohibiting the sale of tobacco on campus, such as prohibiting the delivery of tobacco products to students on campus, can be adopted.

Research is needed on the interplay between larger, macro-level factors, such as state tobacco control policies and interventions, tobacco-free college campus policies, and tobacco use behavior. One study (Ciecierski et al. 2011) found evidence that higher state expenditures on tobacco control programs in the prior year were associated with reductions in the prevalence of daily smoking and of 30-day cigar use among college students. Work by state tobacco control programs on policy, systems, and environmental change, including educational campaigns, may influence the adoption of tobacco-free college campus policies. At the same time, tobacco-free college campus policies reduce the social acceptability of tobacco use. It would be helpful to assess whether changes in norms—specifically those associated with college campus policies that are intended to reduce disparities in tobacco use and exposure to secondhand tobacco smoke—influence other community interventions that may reduce tobacco-related disparities.

Finally, as discussed earlier, young adults with fewer years of formal education have the highest rates of tobacco use compared with others in this age group, and many young adults do not attend college. Tobacco-free college campus policies are just one tool to address tobacco use among young adults. Other strategies are needed to prevent and reduce young adult tobacco use, including among people experiencing disparities, such as state and community tobacco control policies and programs, as well as providing both equitable access to secondary and postsecondary education and equitable support to youth and young adults to help them graduate from their educational programs and further advance their education.

### Healthcare System Interventions

A primary opportunity to develop and disseminate appropriate, comprehensive, and integrated tobacco cessation treatment exists within healthcare settings. Although encounters with healthcare are important opportunities for individuals to be connected to cessation treatments, population groups experiencing tobacco-related disparities may also have inequitable access to healthcare in general or have differences in patterns of healthcare use that limit interactions with the healthcare system (IOM 2003; Yearby 2018; Agency for Healthcare Research and Quality 2021; Lee et al. 2021). Nonetheless, encounters with the healthcare system present opportunities in which people who use tobacco may be receptive to receiving counseling and making a cessation attempt supported by proven quit aids. Thus, while there are opportunities to provide tobacco cessation counseling and treatment during healthcare encounters, interventions integrated into healthcare delivery require careful design to be effective in reducing disparities.

Annually, most U.S. adults who smoke see a healthcare provider at least once (70%), want to quit smoking (68%), and make one or more quit attempts (55%), thus putting healthcare systems in a position to address tobacco use and dependence across populations (Babb et al. 2017) (population-specific cessation indicators are detailed in Chapter 4). The 2008 U.S. Public Health Service’s Clinical Practice Guideline, Treating Tobacco Use and Dependence: 2008 Update (Fiore et al. 2008; hereafter referred to as Clinical Practice Guideline) calls on healthcare providers to assess and document tobacco use, advise and assist patients to quit with the aid of behavioral and pharmacotherapy supports, and arrange for ongoing support to increase the likelihood of cessation.

Systematically addressing tobacco use across healthcare systems, including through systems-level change strategies such as team-based care and health system policies and protocols, should reduce the prevalence of tobacco use and tobacco-related morbidity on average and within priority populations who bear a disproportionate burden of tobacco-related comorbidity, such as people of lower SES, people with disabilities, and those from certain minoritized racial and ethnic groups (USDHHS 2014, 2020). Studies are needed to determine how well this has been achieved and the systematic approaches that have been taken to address disparities in tobacco use and cessation through healthcare systems.

Various healthcare organizations, including those in ambulatory and inpatient settings, have adopted EHR technology that enables systematic tracking of tobacco use status across populations. In addition, health insurance regulations now require greater coverage for tobacco cessation services and cessation medications (DiGiulio et al. 2020), though some of these regulations are currently being challenged in the courts (Sobel et al. 2023). Despite the potential that exists within healthcare systems to systematically address tobacco use, numerous studies continue to document unequal access to cessation care, particularly for populations at risk for tobacco-related health disparities (Cokkinides et al. 2008; Babb et al. 2017, 2020; Bailey et al. 2018; Tan et al. 2018; USDHHS 2020). Disparities in receipt of health professional cessation advice and utilization of cessation treatments are reviewed in detail in Chapter 4. This section highlights promising strategies within healthcare systems that have demonstrated feasibility for systematically addressing tobacco cessation among adults. Studies reviewed here relate to systems-based strategies; individual-level interventions are reviewed elsewhere in this chapter. Due to limited data, definitive conclusions could not be made about the extent to which these strategies reduce tobacco-related health disparities.

#### Tobacco Cessation Treatment in Healthcare Settings

##### Screening and Brief Interventions to Treat Tobacco Dependence

Multiple models of brief tobacco cessation interventions have been researched and used in clinical settings. The 5A’s model is outlined in the Clinical Practice Guideline and includes five components: (1) Asking patients about tobacco use, (2) Advising them to quit, (3) Assessing their readiness to quit, (4) Assisting in their quit attempt by offering counseling and pharmacotherapy, and (5) Arranging for follow-up (Fiore et al. 2008). Two additional models, the Ask, Advise, Refer (AAR) model and the Ask, Advise, Connect (AAC) model (Vidrine et al. 2013), are similar to the Screening, Brief Intervention, and Referral to Treatment (SBIRT) approach that has been used successfully with people who use alcohol and illicit substances (Saitz 2007). In clinical settings, including those serving priority populations, the AAC and AAR models encourage staff and clinicians to initiate tobacco cessation treatment and connect people who use tobacco with treatment programs that may be either within or outside the clinical setting.

The AAC model, in which patients who use tobacco are proactively connected to an existing program for tobacco cessation treatment, is more effective than the AAR model, which can put the onus for follow-up on the patient (Vidrine et al. 2013). The AAC model has been implemented successfully in busy clinics within a safety-net healthcare system (i.e., a system in the United States obligated to provide healthcare for people regardless of insurance status) and can be employed using a team approach, with multiple staff delivering individual components of the overall intervention (Pineiro et al. 2020). Importantly, the AAC approach can successfully leverage the network of state quitlines to proactively reach referred patients and provide counseling, and sometimes pharmacotherapy, in all 50 states, Washington, D.C., and several U.S. territories.

Quitlines are increasingly offering tailored patient education and counseling protocols for priority populations (North American Quitline Consortium 2018) (see the “Tobacco Quitlines” section in this chapter for more information). Similar opportunities are offered by eReferral to no-cost web-based and texting programs, such as those featured by NCI’s Smokefree.gov. Electronic referral to SmokefreeTXT, a text messaging-based smoking cessation program from NCI, has been found to be feasible and acceptable to patients and clinical staff (McCarthy et al. 2019).

Population approaches that employ changes in health systems to address tobacco use represent promising strategies to increase the reach of tobacco cessation treatment. Historically, the default for tobacco cessation intervention has been that people who use tobacco needed to “opt in” to treatment. “Opt-in” services rely on referrals from healthcare providers for treatment, which generally rely on assessments of patient readiness to quit or willingness to engage in cessation services (Richter and Ellerbeck 2015), which limit those who receive cessation treatment. “Opt-out” tobacco consultation services, which offer cessation counseling to all people identified as using tobacco, illustrate the potential for broad reach (Nahhas et al. 2017; Ylioja et al. 2017) and have been proposed as more ethical than opt-in services (Richter and Ellerbeck 2015). Furthermore, opt-out services may more equitably reach population groups such as underserved racial and ethnic groups and individuals enrolled in Medicaid (Faseru et al. 2009; Ylioja et al. 2017). Whether an opt-out or opt-in approach yields superior results was tested in a large clinical trial among hospitalized adults (Faseru et al. 2017; Richter et al. 2023). Data from this trial showed promising results, with opt-out care (vs. opt-in care) achieving better cessation treatment utilization (59.9% vs. 33.8% for medication use and 88.7% vs. 37.1% for engaging in ≥1 postdischarge counseling calls), quit attempts among those who continued to smoke at 1 month (69.2% vs. 59.2%), and 1-month verified abstinence (21.5% vs. 15.9%) (Richter et al. 2023).

##### Ambulatory Care Settings

Although clinical guidelines for tobacco cessation treatment can be effectively implemented in ambulatory care settings (Quinn et al. 2009), few studies have specifically investigated the degree to which such implementation reduces disparities in tobacco cessation. A large trial examining the impact of implementing guidelines for tobacco cessation treatment in clinics for U.S. veterans found higher rates of documenting tobacco use and the use of medications by patients, but no increases were seen in rates of prescriptions for smoking cessation medication or in overall quit rates among patients (Joseph et al. 2004). Subsequent trials of population-based proactive treatment of smoking among socioeconomically disadvantaged groups resulted in higher self-reported long-term abstinence in veterans (Fu et al. 2014b) and people enrolled in state-administered health insurance (i.e., Medicaid or MinnesotaCare, which is for Minnesota residents who do not have access to affordable healthcare coverage, but who have higher income than people covered by Medicaid or Medical Assistance) (Fu et al. 2016). Proactive interventions included study-facilitated access to counseling and NRT that did not require a dedicated visit with a healthcare provider. A secondary analysis of proactive outreach in U.S. veterans did not demonstrate an interaction between race and intervention condition; in that study, African American veterans (13%) quit at higher rates than White veterans (9%, p <0.006), regardless of receipt of proactive or usual care (Burgess et al. 2014). The authors suggested that the higher quit rates among African American veterans may have been due, in part, to a higher likelihood of use of combined cessation counseling and medication in this group in the study. Collectively, these studies support the role of proactive, population-based treatment for people who smoke in a broad array of priority populations. The Veterans Health Administration and state-administered healthcare programs, such as Medicaid, are uniquely equipped to offer proactive tobacco cessation treatment, and thereby have the potential to reduce tobacco-related health disparities, based on their clinical infrastructure and the population groups they serve.

##### Community Health Settings

Studies suggest that leveraging community-based settings and outreach, such as community health centers or community health workers, may effectively increase reach of cessation interventions to population groups with high tobacco use prevalence. Community health centers, for example, are uniquely situated to reach lower-income patients who smoke and they serve a patient population with a high proportion of tobacco use; a study of Federally Qualified Health Centers (FQHCs) found the prevalence of tobacco use to be an average of 5.2 percentage points higher among patients at FQHCs compared with the overall population in their states (range −4.9 to 20.9) (Flocke et al. 2017). A study of smoking cessation behaviors among adult patients at federally supported health centers found that most patients received clinical advice to quit (78.7%), but few used cessation treatment when trying to quit (15.2%), suggesting that there are opportunities to increase treatment engagement (Trapl et al. 2021b).

Involving communities in planning interventions in familiar settings and using the principles of CBPR have produced promising results (described later) in smoking cessation outcomes among American Indian population groups; in intersectional groups of African American women living in subsidized housing; and in neighborhoods within geographic regions where the prevalence of tobacco use remains high, such as “Tobacco Nation,” the 13-state region in the Midwest and South, which has many rural communities and which has some of the highest rates of smoking among adults in the nation (Truth Initiative 2019c).

A culturally tailored group therapy program using the American Indian “talking circle” format with trained American Indian facilitators found higher self-reported but not cotinine-verified cessation after 6 months (Choi et al. 2016a). Elsewhere, a CBPR approach was used to develop a culturally tailored intervention for African American women residing in subsidized housing. The intervention included NRT and was delivered by community health workers through one-on-one visits at participants’ homes or in community settings and reinforced by group therapy led by trained nurses and community health workers. Cessation rates among the population that received the CBPR-developed intervention were higher at 12 months compared to rates among the control group, which received culturally sensitive written materials (12% vs. 5.3%, p = 0.016). However, the CBPR-developed intervention had no statistically significant effect on the odds of having quit smoking in multivariate analyses that included covariates that were statistically significant in univariate analyses, such as baseline number of cigarettes smoked (Andrews et al. 2016).

In a study of racially and ethnically diverse people who smoke and were recruited through community health centers in the southern region of the United States, most (71%) embraced novel treatment approaches, such as genetically informed precision treatment of smoking, but favorable attitudes toward such treatments among African American people who smoke was about half that among White people who smoke (aOR = 0.47; 95% CI, 0.27–0.83) (Senft et al. 2019). A follow-up CBPR study, which used a community advisory board that included African American people who smoke, demonstrated the feasibility of this approach to the cultural tailoring of genetically informed precision treatment (Connors et al. 2019). Other research has successfully recruited African American people who smoke from FQHCs (Sanderson Cox et al. 2012; Webb Hooper et al. 2017a; Nollen et al. 2020).

##### Hospital and Acute Care Settings

Tobacco cessation treatment initiated in the emergency department of a hospital is effective, has been implemented successfully in multiple clinical trials, and was recommended as “an integral component of emergency care” (Bernstein et al. 2006, p. e423) in a joint statement of U.S. emergency medicine organizations (Bernstein et al. 2006; Lemhoefer et al. 2017). Groups who are disproportionately burdened by tobacco use, including African American people, Hispanic people, and people enrolled in Medicaid or who are uninsured have relatively high rates of use of emergency department care (IOM 2003), providing a potential opportunity to increase the reach of cessation interventions to these population groups. The extent to which tobacco cessation treatment initiated in the emergency department reduces tobacco cessation-related disparities is unknown. A systematic review and meta-analysis of RCTs published between October 4, 2010, and May 15, 2015, that considered time points ranging from 1, 3, and 6 months to 12 months after the visit to the emergency department demonstrated higher cumulative odds of cessation for those who received a cessation intervention initiated in the emergency department versus those receiving “usual care” such as self-help materials (pooled risk ratio [RR] = 1.40; 95% CI, 1.06–1.86) (Lemhoefer et al. 2017). However, the meta-analysis did seem to suggest an attenuated effect over time, with significant effect at 1- and 3-months follow-up, but not at 6- and 12-months follow-up.

Hospitalized people who smoke benefit from tobacco cessation treatment that is initiated during their stay. A Cochrane review of 50 hospital-based smoking cessation trials revealed that high-intensity behavioral interventions (but not lower intensity interventions) initiated during a hospitalization, including behavioral counseling support that continued in the month following discharge and NRT, substantially improved tobacco abstinence rates (Rigotti et al. 2012). The benefits of hospital-initiated tobacco cessation treatment were similar in acute care hospitals and rehabilitation hospitals and were optimized if counseling and NRT extended for at least 1 month after discharge. Some evidence subsequent to the Cochrane review supports initiating varenicline before hospital discharge (Eisenberg et al. 2016). In addition, several other studies found continued success from cessation interventions initiated during hospitalization (Rigotti and Stoney 2016), and one study—which highlighted the effectiveness of advice to quit, brief intervention, and arranging for a quitline referral during a tertiary care hospital stay—found no differences by race in long-term abstinence rates (Harrington et al. 2016). These studies illustrate varying degrees of pragmatism, or real-world applicability testing, in addressing tobacco use in clinical populations (Cruvinel et al. 2016) and underscore opportunities to improve rates of cessation at a population level by implementing effective interventions in hospital settings.

Additional tools, such as interactive voice response (IVR) outreach via automated calls (Nahhas et al. 2017) and electronic referral (“eReferral”) to state quitlines (Tindle et al. 2016) to augment postdischarge care, can increase reach by engaging more hospitalized people who smoke to use evidence-based treatment. Strategies such as IVR are typically offered in an opt-in fashion, although precedent exists for an opt-out model (Nahhas et al. 2017).

##### Clinical Oncology Settings

Clinical oncology settings present unique opportunities for effective cessation intervention delivery. Comprehensive cancer care may encompass both ambulatory and hospital settings; promising strategies in each of these settings stand to benefit people who use tobacco and are undergoing cancer screening, diagnosis, or treatment, or are in survivorship after successful treatment. Studies have been conducted to determine how the clinical oncology setting can be used to assist patients with cancer who smoke to quit; however, limited research has focused on cessation among population groups affected by cancer and tobacco-related disparities.

NCI Tobacco Control Monograph 23, Treating Smoking in Cancer Patients: An Essential Component of Cancer Care (NCI 2022) reviewed evidence regarding the importance of cessation treatment in oncology settings, including for groups disparately affected by tobacco use. It concluded that “patients with cancer who are also members of medically underserved and vulnerable populations are motivated to quit smoking” but may be less likely to successfully quit than patients with cancer in the overall population. The monograph also called for further research “regarding the effectiveness of smoking cessation treatment among medically underserved and vulnerable groups of cancer patients” as well as “strategies for increasing the reach and cost-effectiveness of such treatment” (NCI 2022, p. 262).

In 2017, as part of its Cancer Moonshot program, NCI launched the Cancer Center Cessation Initiative (C3I), a program designed to help NCI-Designated Cancer Centers build and implement sustainable tobacco cessation treatment programs to routinely address tobacco cessation with patients in clinical oncology settings (Croyle et al. 2019). C3I aims to support the comprehensive treatment of smoking as a “fourth pillar” of cancer care to be added to the standard surgical, radiologic, and chemotherapeutic approaches to cancer treatment (Fiore et al. 2019). As implementation of smoking treatment in 52 NCI-Designated Cancer Centers proceeds, an opportunity exists to study the extent to which C3I efforts may increase tobacco cessation and improve cancer outcomes in patient populations affected by disparities in tobacco use (D’Angelo et al. 2021).

#### Augmenting the Capacity of Healthcare Providers to Treat Tobacco Dependence

Building provider capacity to address tobacco use is a key component of the successful implementation of tobacco cessation treatment programs in healthcare settings. Some studies have suggested gaps in knowledge among clinicians serving patient populations with lower incomes. For example, a survey of Arkansas primary care physicians caring predominantly for patients who were insured by Medicaid and/or Medicare or were uninsured found that nearly 75% had no training in the treatment of tobacco use and very little knowledge of programs for tobacco cessation treatment provided by the state at no charge (Sheffer et al. 2012a).

Several models of capacity building have been implemented with some success. For example, academic detailing, which involves training providers and clinic staff about tobacco use and its treatment as well as providing technical assistance, increases rates of clinical assessment and treatment of tobacco use (CDC 2014). In one study of primary care clinics in Wisconsin, a combination of enhanced academic detailing (including in-person trainings, technical assistance, and performance feedback to clinic personnel) and a light-touch quitline fax referral implementation program (written implementation guide and clinic-level feedback) increased the average number of quitline referrals per clinician compared with the light-touch program alone (8.5 vs. 1.6 referrals, p <0.001), and also increased the average number of referrals resulting in quitline service enrollment (4.8 vs. 0.86, p <0.001) (Sheffer et al. 2012b).

Learning collaboratives are another example of a capacity-building model in which public health and healthcare collaborate with shared learning and technical assistance to advance health systems change and quality improvement activities for improved integration of tobacco dependence treatment into clinical care (Kaslow et al. 2018). In addition, training in intersectional disparities (the clustering of disparities within an individual person based on belonging to multiple sociocultural population groups) has been suggested as a potential strategy to increase delivery of tobacco cessation treatment that demonstrates sociocultural respect and addresses power imbalances inherent to interactions between providers and patients from marginalized population groups (Sheffer et al. 2018).

#### Electronic Health Records and Associated Decision Support

As part of the Health Information Technology for Economic and Clinical Health Act, health systems received incentives to adopt Meaningful Use^4^ strategies for EHRs. One of the requirements of Meaningful Use for providers, eligible hospitals, and critical access hospitals was the documentation of smoking status for patients 13 years of age and older (Centers for Medicare & Medicaid Services [CMS] 2010). Making appropriate modifications to EHRs (e.g., prompts for screening and intervention or automatizing referrals) appears to increase the population rate of screening for tobacco use and the provision of cessation assistance (Boyle et al. 2014). EHR patient portals and mobile applications delivering eHealth interventions are growing in popularity, but their impact on tobacco-related health disparities is unknown. While having home Internet access is associated with successful tobacco cessation among U.S. veterans (Calhoun et al. 2016), differential access to Internet services may limit the reach of Internet-based interventions. African American people, Hispanic people, and people with lower levels of education are less likely to have access to the Internet, particularly broadband internet at home (Atske and Perrin 2021), potentially increasing disparities for these groups for Internet-based interventions.

EHR systems can support both identification of priority populations and delivery of tobacco cessation interventions. Interventions using EHR data to identify lower SES population groups for proactive outreach interventions have been found to increase the use of cessation aids (Vidrine et al. 2013; Haas et al. 2015) and rates of cessation (Haas et al. 2015). Most EHRs allow for documentation of race and ethnicity, sexual orientation and gender identity, and markers of lower SES, such as insurance status (Federal Register 2012; Cahill et al. 2016). Electronic clinical decision support tools integrated into the EHR can direct healthcare providers to deliver treatment, increase medication orders or prescriptions, and increase referrals to state quitlines for telephone counseling treatment as part of the clinical encounter (Karn et al. 2016; Bernstein et al. 2017). Computerized patient interactions that are translated into languages beyond English can increase engagement with cessation interventions for underserved population groups (Cupertino et al. 2010). EHRs offer healthcare systems the opportunity to identify and systematically deliver proactive tobacco cessation treatment to patients who use tobacco and to evaluate the impact of interventions on tobacco-related health disparities (Kruse et al. 2012; Satterfield et al. 2018).

#### Clinical Quality Programs

Strategies that promote the systematic delivery of tobacco cessation treatment services include clinical quality programs. The 2020 Surgeon General’s report on smoking cessation concluded that there is sufficient evidence to infer that strategies linking cessation-related quality measures with payment increase delivery of clinical cessation treatment (USDHHS 2020). This conclusion continues to be borne out by recent evidence. In Oregon, implementation of an incentive metric for cigarette smoking in the state’s Medicaid coordinated care organization Quality Incentive Program was associated with increases in the percentage of people enrolled in Medicaid who reported receiving clinical advice to quit smoking (Livingston et al. 2020).

Tobacco cessation-related quality programs and related quality measures exist at a variety of system levels, including at the level of the provider, hospital, system, and payer. One example is the inpatient tobacco cessation treatment measures from The Joint Commission, the accrediting body for hospitals (The Joint Commission 2012). Although currently voluntary, the Joint Commission measures include (1) documenting patients’ tobacco use status, albeit not explicitly across all tobacco products (e.g., e-cigarettes), during the hospital stay; (2) documenting the delivery of counseling and pharmacotherapy during the inpatient stay; and (3) documenting provision or offering of outpatient counseling and pharmacotherapy on discharge (The Joint Commission 2012). Inpatient psychiatric facilities have been incentivized to report on the inpatient tobacco-related measures stewarded by the Joint Commission as part of the Inpatient Psychiatric Facility Quality Reporting (IPFQR) Program (CMS 2018). This has led to increases in documentation of the assessment of tobacco use and its treatment since the requirement was first imposed (Scharf et al. 2011; CMS 2014; Carrillo et al. 2017). Recent changes in the IPFQR Program have reduced the tobacco-related measures required for reporting to one measure, the TOB 3/3a measure, beginning with the fiscal year 2025 payment determination year. This measure captures whether referrals to outpatient tobacco cessation counseling and for FDA-approved medications were offered or refused at the time of the patient’s discharge (Federal Register 2023a). The Medicare Shared Savings Program (Shared Savings Program) is an example of a cessation-related quality program at the systems level. Shared Savings Program Accountable Care Organizations (ACOs) assume responsibility for the quality, cost, and experience of care for a defined group of Medicare beneficiaries. ACO performance is evaluated on a set of clinical quality measures that includes tobacco cessation treatment. ACOs that perform well may be eligible to share in the savings they achieve for the Medicare program (also known as performance payments) (CMS 2020). Although such programs drive increases in the delivery of clinical treatments, it remains unclear what impact they have on disparities in the receipt of cessation treatment services.

Health systems are also increasingly being asked to identify, document, and address health disparities including social and structural barriers to care. For example, new 2023 requirements from The Joint Commission require accredited institutions to assess patients’ social needs that impact health (such as transportation, food security, housing security, education and literacy, and ability to pay for medical care) and also provide patients with information about support services (The Joint Commission 2022). The Joint Commission also requires systems to identify healthcare disparities in their patient populations and develop a plan to address at least one of the disparities identified.

Similarly, CMS has added two measures related to social determinants of health to the PPS (prospective payment system)-Exempt Cancer Hospital Quality Reporting (PCHQR) Program (Federal Register 2023b). These measures assess screening and screen-positive rates for food insecurity, housing instability, transportation needs, utility difficulties, and interpersonal safety for all admitted adult patients. PPS-exempt cancer hospitals will be required to report these measures starting in the fiscal year 2027 program year. These measures have been adopted into the Hospital Inpatient Quality Reporting program (Federal Register 2022a). As efforts to address the social and structural barriers to care are implemented, evaluation regarding their impact on supporting tobacco cessation and cessation-related disparities will be needed.

#### The Patient Protection and Affordable Care Act

Comprehensive insurance coverage of proven cessation treatments, particularly when offered without barriers to access, has the potential to impact disparities in treatment access and utilization. The Clinical Practice Guideline concluded that insurance coverage of cessation treatments increases treatment utilization, quit attempts, and successful quitting (Fiore et al. 2008). Similarly, the 2020 Surgeon General’s report concluded that, with adequate promotion, comprehensive and barrier-free treatment coverage increases treatment utilization, leads to higher rates of successful quitting, and is cost-effective (USDHHS 2020).

The impact of the Patient Protection and Affordable Care Act (ACA) (2010) on the delivery of tobacco cessation treatment services to reduce tobacco use and tobacco-related health disparities is largely understudied (Hawkins and Cohen 2014; Burcu et al. 2016). The ACA requires most private health insurance plans, as well as Medicaid alternative benefit plans, in which members of the ACA Medicaid expansion population must be enrolled, to cover tobacco cessation treatment as recommended by the U.S. Preventive Services Task Force, including at least four counseling sessions (without cost sharing) and FDA-approved pharmacotherapy. Copayments for FDA-approved smoking cessation medication may still apply, and they vary by insurance plan, even for Medicare enrollees with plans that include prescription coverage. Gaps in coverage for cessation treatments also remain in traditional Medicaid programs (i.e., with respect to beneficiaries who are not enrolled in an alternative benefit plan), with varying levels of access barriers such as copayments, duration limits, and limits on the number of covered quit attempts (DiGiulio et al. 2020). As of 2018, only 15 state Medicaid programs provided comprehensive cessation coverage to all enrollees in traditional Medicaid (DiGiulio et al. 2020). The ACA requirement that health plans cover preventive care services recommended by the U.S. Preventive Services Task Force is currently being challenged in the courts (Sobel et al. 2023).

In addition, since 2014, the ACA has given states the option to expand Medicaid using Group XIII eligibility (i.e., income less than or equal to 138% of the federal poverty level). In 2015, an estimated 2.3 million people who smoked became newly eligible for healthcare coverage through the expansion of Medicaid programs in 31 states and Washington, D.C. (DiGiulio et al. 2016). Diverse racial and ethnic groups, adults with lower income (Sommers et al. 2015), and people who identified as LGBT (Skopec and Long 2015) reported increases in access to health insurance after this expansion, although gaps in coverage and disparities in healthcare access persist (Lee et al. 2021). Medicaid expansion increased prescriptions for smoking cessation, use of cessation treatment, and cessation rates among newly insured enrollees who smoked (Koma et al. 2017; Maclean et al. 2017; Richards et al. 2017; Young-Wolff et al. 2017). For example, smoking cessation increased among lower income adults in 39 states and the District of Columbia after they expanded Medicaid coverage (Koma et al. 2017). In another study, patients who used tobacco and had visits in community health centers in 10 expansion states (vs. propensity score-matched patients in non-expansion states) had increased adjusted odds of quitting (aOR = 1.35; 95% CI, 1.28–1.43) and having a cessation medication ordered (aOR = 1.53; 95% CI, 1.44–1.62) (Bailey et al. 2020).

These results are consistent with prior studies showing that expanded coverage for tobacco cessation treatment services decreased the prevalence of smoking (Land et al. 2010). States that expanded Medicaid also observed a trend toward earlier stage cancer diagnoses (Jemal et al. 2017) and increases in the rate of surgery for lung cancers (Eguia et al. 2018). Although more people reported having received advice to quit smoking from a healthcare provider from 2010 to 2015 after the ACA rollout, lower prevalence of receiving advice from providers persisted for lower income and Hispanic populations (Tan et al. 2018). (For more information on disparities in receipt of provider advice, see Chapter 4). Earlier research also found that use of NRT was lower among people with lower incomes and among “non-White” adults in one state when NRT was made available without a prescription (Thorndike et al. 2002) (“non-White” was not further defined in the study); instituting coverage without copayment for all FDA-approved cessation medications is one way to address this disparity (Curry et al. 1998).

Collaboration between Medicaid programs and state quitlines may reduce tobacco-related health disparities by increasing access to treatment. For example, the Medi-Cal Incentives to Quit Smoking trial in California (Anderson et al. 2018) conducted statewide outreach to California Medicaid enrollees via a variety of channels, including direct-to-member and direct-to-provider mailings. These communications encouraged enrollees to call the California quitline and promoted incentives for callers, including free NRT and a $20 financial incentive, which quitline callers had to request (Tong et al. 2018b). Groups that asked for the financial incentive at higher rates than average included callers who were African American; American Indian and Alaska Native; pregnant women; or gay, lesbian, or bisexual and callers with some behavioral health conditions (Tong et al. 2018b). Except for callers who were Spanish-speaking Hispanic people, callers who requested the financial incentive generally had higher engagement with the quitline (Vijayaraghavan et al. 2018b). These findings suggest that population-tailored promotional strategies for evidence-based quitlines can help to address disparities in access to care.

#### Summary and Recommendations

Healthcare settings are a critical environment for reaching and engaging people in tobacco cessation interventions, including delivery of evidence-based treatments such as behavioral counseling and pharmacotherapy. Such treatments can be delivered successfully in a variety of clinical settings and by a variety of healthcare professionals (Fiore et al. 2008; USDHHS 2020). As outlined in the 2020 Surgeon General’s report, health system-level changes, such as linking quality measures to payments, can increase the delivery of cessation treatments (USDHHS 2020).

What is less well understood is the impact of such health system changes on reducing tobacco use and health outcomes associated with tobacco use among population groups affected by tobacco-related disparities; the lack of data precludes definitive conclusions about the extent to which these strategies reduce tobacco-related health disparities. To improve understanding of the degree to which health systems interventions aimed at increasing reach of and engagement in cessation reduce disparities, researchers should, wherever possible, report impact among key priority populations, including underserved racial and ethnic groups, lower SES groups, and other priority populations (Brown et al. 2014). Continued research is needed in clinical settings to examine the effectiveness and disparity-related impacts of quality improvement strategies, health systems changes, provider behaviors, patient treatment engagement, and systems change maintenance.

Health technology, quality programs, and other policies can be valuable tools for reducing tobacco-related health disparities. EHRs, for example, are a promising tool for providing systems-level support to providers in the delivery of tobacco cessation treatment (including through clinical decision support, assisted documentation, and facilitation of patient referral to additional cessation supports) and as a data source for evaluating both the delivery of treatment as well as systems-level interventions or quality improvement initiatives aimed at enhancing and improving treatment delivery. However, challenges remain related to data quality and availability. EHR data also have the potential to facilitate the identification of barriers to implementing consistent treatment throughout healthcare systems, including potentially identifying whether there are unique or disproportionate treatment barriers, such as social and structural barriers, as more health systems are documenting social determinants of health.

As noted in the 2020 Surgeon General’s report, health system regulations that require providers to document the provision of tobacco cessation treatment can increase the clinical delivery of tobacco cessation treatment in healthcare settings, particularly if doing so is tied to reimbursement. Policies that increase access to services, such as those instituted by the ACA and the expansion of Medicaid, are essential to reducing tobacco-related health disparities.

For the healthcare systems’ “window of opportunity” to open widest, systematic documentation of tobacco use status, along with delivery and documentation of counseling and pharmacotherapy, are critical. Ensuring the systematic provision of cessation interventions across healthcare settings can reduce existing gaps in the delivery of tobacco cessation treatment to population groups experiencing a high prevalence of tobacco use and poor tobacco-related health outcomes. Continuation of standard practice, which generally relies primarily on providers to deliver advice to stop smoking and make referrals for treatment, is likely to perpetuate tobacco-related disparities. Widespread implementation of proactive, health system-level treatment models is needed, as is better understanding of the impact of systems-level approaches (e.g., systems policies and protocols that routinize and standardize care, team-based care models, and others) on cessation-related disparities. Clinical practice guidelines and recommendations to offer tobacco cessation treatment services to every patient at every encounter in all healthcare settings by any healthcare professional remain paramount (Fiore et al. 2008). Also needed are continued efforts to increase access to healthcare for underserved population groups as well as efforts to expand the reach of cessation interventions by leveraging the full continuum of healthcare settings, including through pharmacists and cancer screening programs.

Implementing these recommendations to reduce tobacco-related health disparities will be further supported by ensuring that provider training includes tobacco cessation treatment (and the role of disparities), leveraging EHR-enabled technological advances to systematize treatment delivery, and using existing and potential regulatory requirements, particularly those that are tied to reimbursement. As integration of tobacco use treatment in healthcare settings continues to proceed, an urgent need exists for research to document the impact of such treatment on tobacco-related health disparities and to guide clinical practice to ensure the consistent and equitable delivery of evidence-based treatment to everyone who uses tobacco. As more health systems work to address social determinants of health, studies are also needed to determine how well social determinants of health are being documented in the medical record, evaluate the impact of social determinants of health interventions, and determine the impact of such interventions on patients’ ability to fully benefit from tobacco cessation programs.

### Worksite-Based Interventions

The prevalence of smoking, quitting, and relapse differs significantly by occupation (see Chapters 2 and 4 for additional details). Occupation is a critical indicator of SES as it links education and income and reflects a person’s place in society related to their social standing as well as their working conditions and relationships (Galobardes et al. 2006). Whether a person is employed or not—and for those who are employed, the nature of one’s working conditions—significantly shapes health outcomes, exposure to occupational hazards, and health behaviors like tobacco use (USDHHS 1985; Schnall et al. 2009; Marmot and Bell 2010; Pfeffer 2018). Occupation influences tobacco use patterns through job-specific working conditions, the availability of worksite resources to support cessation and prevent relapse, and tobacco policies that further contribute to the work environment.

This section discusses social, organizational, and healthcare policies and relationships that either facilitate or pose barriers to addressing tobacco-related disparities at worksites, with an emphasis on the implications for lower income and “blue-collar” workers (i.e., manual laborers or other workers who perform work with their hands, physical skill, and energy) (U.S. Department of Labor 2019). This discussion focuses on three major themes related to the work environment: (1) eliminating disparities in access to cessation resources, (2) eliminating disparities in coverage of tobacco-free policies, and (3) improving working conditions to support tobacco control. This section does not address tobacco use among people who are not employed due to disability, retirement, school attendance, or difficulty finding work. Strategies are also needed to (a) prevent and reduce tobacco use and provide cessation services to all people, regardless of employment status, and (b) provide equitable access to safe employment and opportunities for occupational advancement.

#### Eliminating Disparities in Access to Cessation Resources

##### Improving Social Policies

Health Plan Coverage. Comprehensive coverage for cessation treatment and barrier-free access to such treatment are associated with higher long-term quit rates and improved health outcomes (Kaper et al. 2005; van den Brand et al. 2012; Ku et al. 2016). Historically, health insurance coverage for smoking cessation has been unequally distributed by occupational class, with health insurance plans for “blue-collar,” including physical labor or trade workers, tending not to cover smoking cessation treatments or frequently requiring copayments and prior authorization, all of which pose significant barriers for lower income workers to access cessation treatment (Barbeau et al. 2001a).

As described in prior sections of this chapter, the ACA includes provisions that increase coverage of cessation treatment services. This increase in coverage may reduce disparities in accessing cessation treatment coverage among physical labor and trade workers and lower wage workers. Additionally, the ACA gives states the option to expand Medicaid to lower income workers who were previously ineligible for Medicaid, many of whom are underinsured in part because of their type of employment (such as workers employed in ride sharing, food delivery, and, in some cases, food service). The expansion of Medicaid to this population in some states has increased access to preventive health services, including treatment for smoking cessation, among lower income workers (Williamson et al. 2016). One critical component of the efforts necessary to fully realize the goal of eliminating tobacco-related health disparities in this population is to ensure full compliance with the law among health plans and state Medicaid plans. Continued monitoring of the ACA’s impact on increased expansion of access to cessation treatment among physical labor or trade workers and lower income workers is also important, given the higher prevalence of tobacco product use among these groups (see Chapter 2).

One provision of the ACA (2010) allows certain health insurance plans offered by small employers to charge premiums for people who use tobacco that are up to 50% higher than premiums for people who do not use tobacco. These premiums, also known as tobacco surcharges, are to be used only if an employer provides a tobacco cessation program and the employee does not participate in that program. Although intended to motivate employees who currently smoke to quit, Pesko and colleagues (2018) concluded that tobacco surcharges have been misused by 47% of small employers’ health plans, which imposed these surcharges without offering a tobacco cessation program to their employees.

Although charging people who use tobacco more for health insurance could motivate them to quit, such charges could also cause people to conceal their smoking status to avoid the additional charges, which would make it harder to identify people who smoke and engage them in cessation treatment (Kaplan et al. 2014; USDHHS 2020). Such surcharges could also disproportionately increase healthcare access barriers for those with higher tobacco use prevalence. A recent study of ACA marketplace plan enrollment suggested an association between tobacco surcharges and reduced health insurance enrollment overall, as well as a reduced share of enrollees reporting tobacco use, particularly among people living in rural areas (Dorilas et al. 2022). Only limited data are available regarding the effect tobacco surcharges have on tobacco cessation and on ways to design price differentials that can minimize their potential negative impacts and promote tobacco cessation (USDHHS 2020). Efforts to ensure that employer-based health plans comply with the provisions of the ACA may help to avoid the negative consequences of these surcharges on workers.

Wage Policies. Occupations with lower wages are closely linked to multiple risk behaviors, including cigarette smoking and such consequent adverse health outcomes as reduced life expectancy and premature mortality. The association between lower wages and cigarette smoking operates through various pathways, including poorer material conditions (such as poorer housing, higher debt load, lack of access to a car) and psychosocial factors (such as lack of social support, lower sense of control) (Sorensen et al. 2004).

Studies have shown that people who smoke cigarettes earn between 2% and 24% lower wages than people who do not smoke, and that this wage gap—or “smoking wage penalty”—may be greater among women than men (Darden et al. 2021). This wage gap could contribute additional stress and impact tobacco use. Studies suggest that when people face multiple forms of stress, including financial stress, they may be more likely to smoke (Slopen et al. 2012, 2013). Financial stress for people who use tobacco may be further affected by increases in tobacco prices or tobacco-related health insurance surcharges.

Increased wages have the potential to directly help lower income workers to improve their material conditions and reduce daily stressors, potentially reducing their reliance on smoking as a form of coping with daily stressors and aiding them with accessing resources for smoking cessation. Emerging, albeit limited, evidence suggests possible benefits of increasing minimum wages on improving health equity and various outcomes, including improved access to healthcare (McCarrier et al. 2011), fewer low birth weight births and post-neonatal deaths in the year following birth (Komro et al. 2016), reduced premature mortality (Tsao et al. 2016), and reduced tobacco consumption (Lenhart 2017).

More research is needed to examine the long-term impact of raising minimum wages on tobacco use, quitting, and tobacco-related health outcomes among lower income workers.

##### Workplace Access to Cessation Resources

Evidence from a 2014 Cochrane review on workplace interventions for smoking cessation found that group therapy programs, individual counseling, pharmacotherapies, and programs with multiple intervention components aimed at smoking cessation increase cessation rates compared with no treatment or minimal intervention controls (Cahill and Lancaster 2014).

Workplaces are an important setting in which to assist people in quitting smoking, given that they may contain large groups of people who smoke who can be easily reached and given assistance through proven cessation methods (Cahill and Lancaster 2014). Also, a recent study by Rigotti and colleagues (2020) showed that employers can potentially enhance the impact of providing comprehensive health insurance coverage of smoking cessation medication by adding a phone-based worksite cessation program.

Employer support for uniform Availability of, and access to, cessation resources. Input, support, and commitment from employers and management for a comprehensive health and safety program for workers are key to ensuring a supportive work environment where workers can access tobacco cessation resources, quit successfully, and be protected from exposure to secondhand tobacco smoke (Castellan et al. 2015). The delivery of tobacco cessation programs designed to reach lower income workers could be informed by understanding employers’ perspectives on workplace health promotion programs, such as tobacco cessation programs; what they perceive to be the barriers and facilitators for implementing such programs; and how to address their concerns about costs, time constraints, and logistical issues.

In one study, Hannon and colleagues (2012a) examined the perceptions of workplace health promotion programs among midsized employers in lower wage industries and found that these employers recognized the benefits of these programs in reducing healthcare costs and improving workers’ morale and productivity. Employers expressed concerns about the potential of such programs to intrude into workers’ personal lives; the barriers to implementing such programs, including limited budgets and staff time; and limited ability to reach workers who were geographically dispersed in multiple locations (Hannon et al. 2012a,b). Addressing employer and management concerns about the capacity to implement workplace health promotion programs by providing technical assistance for capacity building within the workplace, offering toolkits or “turnkey” materials and resources that can be directly disseminated to workers, and obtaining evidence that programs will have a positive effect are recommended to increase employer support and commitment.

Financial incentives: Implications of approaches derived from behavioral economics. Based on a systematic review completed in 2010 (Leeks et al. 2010), the Community Preventive Services Task Force recommends worksite-based incentives or competitions combined with additional cessation interventions to reduce tobacco use among workers. The review included evidence from 14 studies evaluating worksite incentives (individual rewards and lotteries) implemented with additional cessation supports (such as self-help materials, cessation support groups, and telephone counseling). These studies occurred in a variety of worksite settings with more than 100 employees, including manufacturing plants, healthcare facilities, government offices, and chemical plants, in both urban and suburban settings. Among the studies reviewed, the authors found a median change of 4.3 percentage points in self-reported cessation and a median quit rate of 15%. The authors did note limitations in the reviewed studies, including attrition rates, and called for additional evaluation of the use of worksite interventions when implemented alone without additional cessation supports (Leeks et al. 2010).

A more recent review by Cochrane in 2019 concluded that there is high-certainty evidence that incentives improve smoking cessation rates among adults at long-term follow-up. Ten of the 33 studies included in the review were done at worksites (Notley et al. 2019) where various financial incentives, including lotteries, prize draws, cash rewards, and vouchers for goods were used to increase participation in smoking cessation programs and for smoking abstinence (Notley et al. 2019).

In three large RCTs that were conducted among U.S. workers and included in the 2019 Cochrane review (Notley et al. 2019), financial incentives had positive effects on biochemically verified smoking cessation (Volpp et al. 2009; Halpern et al. 2015, 2018). Most of the participants in these studies were White, had completed relatively high levels of education, held jobs within “white-collar” industries, and had employers who had used a wellness program.

Future research regarding worksite-based financial incentives for cessation could benefit from a focus on lower income workers and workers in industries with higher tobacco use prevalence. As interventions are developed and implemented, caution must be taken to minimize the use of incentives that have the potential to be discriminatory or coercive (Madison et al. 2011, 2013) (e.g., “incentives structured as rewards [becoming] sufficiently like penalties that they undermine voluntariness” [Madison et al. 2011, p. 459]). Evidence pertaining to the use of incentives for cessation among people with lower SES, but not specific to the worksite, is detailed later in the chapter.

##### Reducing Work-Related Barriers to Accessing Resources

Workers in physical labor, trade, and service occupations often face significant structural barriers that prevent them from fully participating in health promotion programs that include tobacco cessation treatment services (Sorensen et al. 2004). It is critical to understand and reduce such barriers. For example, transit workers’ split-shift schedules (i.e., being on duty in the morning and then again in the afternoon or evening rush hours) and early morning shift hours were cited in focus groups as structural barriers to their being able to attend cessation treatment classes or appointments during office hours or in the evenings (Cunradi et al. 2015). In addition, long working hours among these workers contribute to physical and mental fatigue at the end of the workday and may deter them from participating in treatment programs after work (Cunradi et al. 2015).

Physical labor and trade, lower wage, and service workers also face barriers imposed by their supervisors or line managers, who act as gatekeepers to the workers’ access to health promotion activities during work hours. Other barriers include working overtime, having multiple jobs, long commuting times, and having competing responsibilities at home (Sorensen et al. 2004). To address these structural barriers and improve support for these workers to participate in tobacco cessation treatment, those who implement tobacco cessation treatment programs need to engage with employers and managers to obtain their buy-in and support for worker health and safety. Contextual factors, on-the-job demands, and work routines that vary across industries (such as transit, manufacturing, construction, extraction, service, and hospitality) should all be recognized and then addressed to structure cessation programs more flexibly around workers’ schedules, break times, and locations.

##### Engaging Labor Unions in Tobacco Control Efforts in the Workplace

Labor unions have played a critical role in public health, including by improving working conditions—such as setting working-hour limits and other protections against workplace hazards—and creating standards for higher wages and benefits (Malinowski et al. 2015; Hagedorn et al. 2016; U.S. Bureau of Labor Statistics 2020b). These benefits not only accrue to workers in unionized settings, but they frequently help set norms for other employers as well (Freund 2022).

Despite resistance from some unions (at times due to tobacco industry influence, including industry attempts to form alliances with unions over topics such as excise taxes and workplace smoking restrictions), other unions have engaged effectively with tobacco control efforts (Barbeau et al. 2005; Malinowski et al. 2015). For example, the flight attendants’ union played a crucial role in the adoption of the federal airline smoking ban, discussed earlier in this chapter (Balbach et al. 2005). Other examples include union support for a New York state tobacco tax (Barbeau et al. 2001b) and smoking restrictions in New York City bars and restaurants (Levenstein et al. 2005). More broadly, unions have advocated for the creation of workplace smoking cessation programs and union-based coverage for such programs and have recently advocated for smokefree workplaces (Sorensen 1996; Barbeau et al. 2001b, 2004, 2006, 2007; Ringen et al. 2002; Sorensen et al. 2002, 2004; Osinubi et al. 2003). Given these important past engagements, it is imperative that tobacco control advocates and other stakeholders in public health partner with unions and actively reach out to organized labor to ensure that their input is included in tobacco control policies and related efforts.

#### Eliminating Disparities in Smokefree Policies in the Workplace

As discussed earlier in this chapter, comprehensive smokefree policies in workplaces are associated with reduced exposure to secondhand tobacco smoke, reduced tobacco use, and improved health outcomes among various occupational groups who are disproportionately affected by exposure to smoke in the workplace, such as bar, restaurant, and casino workers (Evans et al. 1999; Brownson et al. 2002; Fichtenberg and Glantz 2002; Allwright 2008). As of February 2022, it was estimated that only 62.3% of the U.S. population is protected by a 100% smokefree workplace, restaurant, and bar law, owing to gaps in the adoption of smokefree laws (American Nonsmokers’ Rights Foundation 2022a).

Service and manual labor workers—such as those who are employed in bars, restaurants, casinos, and construction—are less likely than “white-collar” workers to be protected by smokefree policies in the workplace (NCI 2017a). Given that smokefree policies can support cessation, this gap in smokefree policy coverage among service and manual labor workers may be associated with these workers being more likely than other workers to have ever smoked, to currently smoke daily, to smoke more heavily, and to have less success in quitting (Alexander et al. 2010; NCI 2017a). Consistent with the recommendation earlier in this chapter, greater efforts to enact, implement, and enforce comprehensive smokefree restrictions at state, territorial, tribal, and local levels are needed to reduce tobacco-related disparities among service, physical labor, and trade workers.

#### Improving Working Conditions to Support Tobacco Control Efforts

With increasing attention over time being given to the organizational structure of work environments and to psychosocial working conditions, new policy and programmatic initiatives are being instituted to promote positive working conditions (International Labour Office 2001; IOM 2005; National Institute for Occupational Safety and Health [NIOSH] 2008, 2016; WHO 2010; McLellan et al. 2012, 2017; University of California–Berkeley 2016; University of Massachusetts–Lowell 2017). Although these initiatives are designed to address the health, safety, and well-being of workers in a broad sense, such efforts are likely to strengthen tobacco control efforts as well. For example, one study documented that an integrated health promotion and health protection intervention combining joint worker-management participation, interventions for management to reduce occupational exposures to hazards, and interventions for individuals to reduce smoking significantly improved tobacco cessation among workers in manufacturing settings compared with an exclusive focus on health promotion (Sorensen et al. 2002).

In 2017, NIOSH created the Total Worker Health program, which aims to integrate workplace interventions through policies, programs, and practices to protect workers from workplace hazards and to advance the overall well-being of workers through improvements in working conditions (NIOSH 2017). The Total Worker Health program complements similar efforts by other groups, for example, the Robert Wood Johnson Foundation’s (2016) Culture of Health initiative and framework. This framework, rooted in equity, covers a broad range of health and safety outcomes for workers and is aimed at providing all individuals, regardless of sociodemographic characteristics, with opportunities to thrive. Many of these strategies are discussed by Quelch and Boudreau (2014) and Flynn and colleagues (2018). Similar recommendations have also been made by WHO and colleagues (2018) and the European Network for Workplace Heath Promotion (European Network for Workplace Health Promotion 1997; WHO 1997, 1999; IOM 2005; Carnethon et al. 2009; Hymel et al. 2011; International Association for Worksite Health Promotion 2012) and in the United Kingdom in the form of standards that support management practices to redress workplace stressors (Cousins et al. 2004; Marmot and Bell 2010).

Continuous improvement systems, which aim to improve efficiencies and quality within organizations (e.g., workplace design, work assignments and processes), have promoted innovations in working conditions through the increased participation of employees (Manuele 2014; von Thiele Schwarz et al. 2015; Benders et al. 2017). The benefits of this systems approach include improved health and wellness behaviors (Bertera 1990, 1993; Maes et al. 1998; Sorensen et al. 1998, 2002, 2005, 2007; Elliot et al. 2007; Okechukwu et al. 2009; Olson et al. 2009), enhanced rates of employee participation in health promotion and wellness programs (Hunt et al. 2005), and reduced costs (Goetzel et al. 2001). These findings are supported by multiple reviews of health promotion interventions integrated into the workplace (IOM 2005; Sorensen et al. 2011; Goetzel 2012; NIOSH 2012; Cherniack 2013; Pronk 2013; Anger et al. 2015; Cooklin et al. 2016; Feltner et al. 2016). These integrated approaches (e.g., smoking cessation as well as safety initiatives and process improvements to reduce or eliminate exposure to other substances that may cause lung disease) may be of particular importance for reducing tobacco-related disparities if they are offered to low-wage workers or workers who work in occupations with high levels of smoking prevalence (Baron et al. 2014; von Thiele Schwarz et al. 2015).

#### Hiring Policies Based on Tobacco Use

As of October 2022, 29 states and the District of Columbia have laws that preclude employers from making hiring decisions based on whether one uses tobacco products, unless being tobacco-free is a bona fide qualification for the position (Patel and Schmidt 2017; American Lung Association n.d.). Most of these laws were enacted in the late 1980s and early 1990s, often with tobacco industry involvement (Patel and Schmidt 2017). A number of employers—including health organizations and healthcare providers—in states where employers are allowed to make hiring decisions based on one’s tobacco use status have established hiring policies that exclude people who use tobacco (Sulzberger 2011; Jones et al. 2014).

As more employers have adopted hiring policies that exclude people who use tobacco products, the issue has become the subject of increased debate in the public health community. The rationale for these hiring policies is that smoking conflicts with the employer’s mission to promote personal health and healthcare in general, as well as to increase worker productivity and reduce healthcare costs (Asch et al. 2013; McDaniel and Malone 2014; Legault and Pasternak 2020). Further, some contend that the policies may help to denormalize smoking among jobseekers, current employees, and healthcare patients (Voigt 2012; Olsen 2014). Those opposed to such policies have argued that, because tobacco use prevalence is higher among people of lower SES and other groups experiencing tobacco-related disparities, those people will be most affected in terms of having fewer employment opportunities, less access to employer-based cessation resources for addictive products, and possibly less successful cessation outcomes because of the impact of stigma on the basis of tobacco use (Houle and Siegel 2009; Voigt 2012; Schmidt et al. 2013; Brown-Johnson et al. 2015).

The impact of these hiring policies on the prevalence of tobacco use among the general population or among those who experience tobacco-related disparities has not been evaluated. Future research should assess the impact of organizational hiring policies based on tobacco use across various occupational settings and the reduction or exacerbation of disparities in (1) the prevalence of tobacco use and (2) economic well-being, such as measures of food security, housing, and other factors that impact health.

#### Summary and Recommendations

Employment status, occupational position, wages, and workplace conditions are linked with tobacco-related health disparities (Marmot et al. 2012). Improving the social, economic, and working conditions of people experiencing disparities is important to successfully reduce and ultimately eliminate tobacco-related and other health disparities. Key steps to reduce tobacco-related disparities include increasing access to comprehensive and barrier-free tobacco cessation services; expanding smokefree and tobacco-free policies to cover all workplaces, with no exemptions for specific industries; and eliminating structural barriers to obtaining cessation treatment services. Critical to achieving these objectives is engaging with and obtaining the support of stakeholders—including employers, managers, employees, and labor unions—and to holistically promote the health, safety, and well-being of all workers.

## Interpersonal-Level Interventions

Social influences can include an array of interpersonal factors that consist of social networks or ties, social support, and social norms (Emmons et al. 2007). These interpersonal factors have the potential to influence an individual’s health or health behaviors (Emmons et al. 2007), including commercial tobacco use, and may have the potential to increase or decrease tobacco-related health disparities (McLeroy et al. 1988; Emmons et al. 2007). Social factors may function as either modifying conditions or mediating mechanisms in conceptual models elucidating the impact of social context on behaviors (Bandura 2001). Social factors that influence a person’s tobacco use may include exposure to tobacco use in various settings, particularly within the home or other personal settings (see Chapter 4); the tobacco use patterns of family members and friends; and cultural norms and beliefs. Interventions involving or addressing social influences may affect tobacco-related health disparities. This section synthesizes promising practices related to creating smokefree rules for households and engaging social support to reduce tobacco-related disparities.

### Household Smokefree Rules

Having rules in place for a smokefree home is associated with decreased exposure to secondhand tobacco smoke and increased smoking cessation (Mills et al. 2009; CDC 2010; King et al. 2013b; Haardörfer et al. 2018; Vijayaraghavan et al. 2018a). The prevalence of homes with smokefree rules varies by race and ethnicity, by the presence of a person who smokes tobacco products in the home, and by SES, among other factors (see Chapter 4) (Orton et al. 2014; Kruger et al. 2015; Zhang et al. 2015b; Vu et al. 2020; Rivard et al. 2021). Interventions that promote comprehensive rules for smokefree homes among lower SES households and other population groups living in homes where smoking is not prohibited by an ordinance, public housing regulations, or a property management policy have the potential to reduce disparities related to both exposure to secondhand tobacco smoke and tobacco use.

#### Interventions to Reduce Exposure to Secondhand Tobacco Smoke in the Home

Although several systematic reviews conducted over the past decade examined intervention studies for smokefree homes, these studies were typically framed as interventions to reduce exposure to secondhand tobacco smoke among young children rather than reducing exposure to secondhand tobacco smoke more broadly through the adoption of smokefree home rules, and they did not address tobacco-related health disparities.

For example, Rosen and colleagues (2015) reviewed controlled trials of interventions designed to reach parents or caregivers of children 0–12 years of age that had objective measures of exposure to secondhand tobacco smoke through measurement of airborne nicotine or particulate matter. Of the seven such studies published between 2009 and 2014, four included children with no health problems, and three included children with asthma or babies in the neonatal intensive care unit with high respiratory risk. Almost all the interventions included 1–10 home visits and a variety of behavior change tools, from cessation counseling to giving feedback on biochemical or air pollution to providing educational materials. The review concluded that all the interventions were effective in reducing, but not eliminating, secondhand tobacco smoke in the home.

Later, a Cochrane review conducted by Behbod and colleagues (2018) examined 78 studies published through early 2017 that aimed to reduce exposure to tobacco smoke among infants and children under age 12 through various mechanisms such as smoking prevention, cessation, health promotion, sociobehavioral therapies, education, clinical interventions, and others. Only 20 studies used objective measures of exposure to secondhand tobacco smoke. This review included controlled trials with or without randomization of parents, family members, teachers, and childcare workers. These studies used various interventions including different types of counseling (in person or via telephone) and educational materials; had different levels of intervention (ranging from brief advice to multicomponent interventions), and were conducted in different populations (community level, school level, ill children, and well children). Only 26 of the 78 studies found evidence of reduced exposure to secondhand tobacco smoke among children as a result of the intervention, with 24 studies reporting statistically significant findings. The intervention most frequently used in these 24 studies was counseling, though heterogeneity in the type and intensity of counseling was observed. Counseling was also the intervention used in 29 of 52 studies that did not find any intervention effects. The authors judged all studies included in the review as being of low or very low quality evidence and having high risk of bias. Additionally, limitations of these studies included variation of study interventions and populations and having insufficient sample sizes leading to low statistical power to detect differences. Thus, the authors were unable to find discernible patterns in the effectiveness of the interventions by intervention type.

Neither of these reviews focused explicitly on interventions developed for populations experiencing tobacco-related health disparities, and few of the interventions were explicit about reaching populations with disparities in exposure to secondhand tobacco smoke or in the prevalence of smokefree home rules. Some of the interventions focused on reducing the number of cigarettes smoked in the presence of children rather than on prohibiting smoking in the home, and others emphasized cessation rather than restrictions on smoking in the home. Overall, the reviews provide limited evidence about the effectiveness of interventions focused on reducing smoking prevalence with respect to reductions in childhood exposure to secondhand tobacco smoke.

#### Interventions Focused on Creating Smokefree Homes

Because of the potential benefits of smokefree homes for people who smoke as well as those in the home who do not smoke, interventions are available that focus directly on the creation of smokefree homes in a variety of household types. Table 7.6 describes intervention research conducted in the United States that focused on smokefree home rules, including exposure to secondhand tobacco smoke among populations who experience tobacco-related health disparities.

Stotts and colleagues (2020) conducted a RCT that analyzed the effect of an intervention in which mothers, primarily of lower SES and from a minoritized racial or ethnic group, received financial incentives for attending motivational interviewing sessions compared with the effect of usual care (one educational session) on urine cotinine levels postdischarge among infants who had been admitted to the neonatal intensive care unit at a children’s hospital. No statistically significant differences were seen between the experimental condition and usual care in the urinary cotinine levels of infants at 2- and 6-month follow-up postdischarge. Reduced infant urinary cotinine levels were observed, however, among participants who completed the experimental intervention as intended (participated in three motivational interviewing sessions, including an initial session at the hospital or in the home and two follow-up sessions in the home, within 6 months of discharge) relative to the usual care condition. In terms of the intervention affecting the prevalence of smokefree rules for the home and car, the exposure to motivational interviewing plus financial incentives was associated with a greater likelihood of reporting a voluntary, total ban on smoking in the home and car as compared with those in the usual care condition at 2 weeks (RR = 1.32; 95% CI, 1.06–1.64) and 2 months (RR = 1.24; 95% CI, 1.01–1.52) after discharge, but not at 6 months after discharge.

Three separate RCTs (Kegler et al. 2015; Mullen et al. 2016; Williams et al. 2016) examined a brief intervention that focused explicitly on creating smokefree homes in lower income households. The intervention, which consisted of one coaching call and three mailings of printed materials among lower income population groups recruited through 2-1-1 call centers, resulted in significantly more participants reporting smokefree home rules at 6-month follow-up compared to control participants. (By calling 2-1-1, people can receive information about social services in their area.) None of the participants in these three trials had smokefree home rules at baseline. For all three trials, eligible participants included an adult who smoked with at least one child or other adult in the home who did not smoke, or an adult who did not smoke who lived with at least one adult who smoked. These three studies allowed for inclusion of households with no children in the home to test the intervention with higher generalizability to the general population.

Table 7.6 Intervention studies to promote smokefree homes among populations with tobacco-related health disparities

Study | Design, population, data collection, and location | Intervention type, contact type, and length | Smokefree homes rate, baseline, and longest follow-up | Primary outcome
Prokhorov et al. (2013) | - RCT; - Latino (Mexican American origin); - 91 households:; – 70% female; – 66% of people smoked; - No SES data available; - Data collection: 0, 6, and 12 months; - Houston, Texas | - Project staff conducted home visits at baseline to deliver culturally appropriate intervention materials (two fotonovelas [novels with photos] for adults and one comic book for children promoting tobacco-free indoor air); - One contact | - Higher rates of smokefree homes in intervention group compared with control group at 12 months (p <0.001); - Intervention: 73% smokefree homes; - Control: 56% smokefree homes | - Decreased air nicotine level in intervention condition compared with control condition at 12 months (per air nicotine monitoring over 7 days); - Significantly greater decrease in air nicotine levels in intervention households compared to control (p <0.05)
Eakin et al. (2014) | - RCT; - 350 caregivers of children enrolled in Head Start (16 sites in Baltimore):; – 92% African American; – 50% with annual household income <$20,000; - Data collection: 0, 3, 6, and 12 months; - Baltimore, Maryland | - Five phone counseling sessions (initially two home visits but protocol changed); - Four sessions offered over 3 months, plus one booster session after the 3-month assessment; - Prioritized smokefree home but addressed cessation | - Smokefree homes increased in both groups:; – Intervention = 21% at baseline versus 39% at final follow-up; – Control = 29% at baseline versus 41% at final follow-up; – Results were not significant | - Reduction of exposure to secondhand tobacco smoke via air nicotine monitoring over 7 days; - Significantly lower household air nicotine at 12 months among the intervention versus control group (0.29 mg vs. 0.40 mg, p <0.05)
Kegler et al. (2015) | - RCT; - Recruited via 2-1-1 call centers (i.e., 2-1-1 callers); - 498 participants:; – 83% African American; – 56% with annual household income ≤$10,000; - Data collection: 0, 3, and 6 months; - Atlanta, Georgia | - Three mailings and one coaching phone call after the first mailing; - 6 weeks | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking) showed a significant intervention effect:; – Intervention: 0% at baseline versus 40% at final follow-up; – Control: 0% at baseline versus. 25% at final follow-up; – p = 0.002 | - Smokefree home rule; - Validated with air nicotine monitoring; - Significantly lower mean nicotine concentration in homes where participants had reported a complete smokefree home rule (0.75 micrograms/m^3^) than homes without a complete rule (3.57 micrograms/m^3^; p <0.001)
Mullen et al. (2016) | - RCT; - 508 English-speaking, 2-1-1 callers:; – 65.2% African American; – 12.0% Latino; – 49.6% with annual household income ≤$10,000; - Data collection: 0, 3, and 6 months; - Houston, Texas | - Three mailings and one coaching phone call after the first mailing; - 6 weeks | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking) showed a significant intervention effect:; – Intervention: 0% at baseline versus 63% at final follow-up; – Control: 0% at baseline versus 38% at final follow-up; – p <0.0001 | - Smokefree home rule
Williams et al. (2016) | - RCT; - 500 callers:; – 61% African American; – 48% with annual household income ≤$10,000; - Data collection: 0, 3, and 6 months; - North Carolina | - Three mailings and one coaching phone call after the first mailing; - 6 weeks | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking) showed a significant intervention effect:; – Intervention: 0% at baseline versus 43% at final follow-up; – Control: 0% at baseline versus 33% at final follow-up; – p = 0.02 | - Smokefree home rule
Stotts et al. (2020) | - RCT; - Cotinine levels of mothers (n = 360) and their infant; - Mother-infant dyad recruited while the infant was in a NICU; primarily of lower SES and from minoritized racial or ethnic group; - Data collection: 0, 2, and 6 months postdischarge; - Houston, Texas | - Two motivational interviewing sessions delivered in the hospital, and two additional counseling sessions given at home 2 weeks apart after NICU discharge; - Financial incentives for session attendance and negative infant cotinine tests postdischarge; - 4 weeks | - Intervention: 29% at baseline versus 57% at final follow-up; - Control: 33% at baseline versus 57% at final follow-up; - p = 0.97 (not significant) | - Urine cotinine level of infant at follow-up; - No significant effect of intervention on level of cotinine in infants, except among mothers who reported high readiness and ability to protect infants at baseline (p ≤0.01) and mothers who completed the study within 6 months postdischarge (p ≤0.05)

Notes: NICU = neonatal intensive care unit; mg = milligrams; RCT = randomized controlled trial; SES = socioeconomic status.

In the trial by Kegler and colleagues (2015), after the 3-month follow-up interview, participants were asked to place monitors in their homes to measure levels of nicotine in the air in order to validate self-reported smokefree home rules. The mean nicotine concentration was significantly lower in homes where participants had reported a complete smokefree home rule (mean = 0.75 micrograms/m^3^) than homes without a complete smokefree home rule (mean = 3.57 micrograms/m^3^; p <0.001). Moderator analyses of pooled data from the three trials showed that the intervention was equally effective across races and ethnicities, education levels, and income groups—whether or not children were present in the home—and with varying numbers of people in the home who smoked (Kegler et al. 2019). However, the intervention was more effective for study participants who did not smoke (and who lived with someone who smoked) versus participants who smoked, and, among people who smoked, those who did not smoke daily versus people who smoked daily, and people who did not smoke within 30 minutes of waking versus those who did (Kegler et al. 2019). A follow-up study assessed outcome evaluation results from implementation of this intervention through a national grant program (Bundy et al. 2020). The rate of establishing a smokefree home rule was comparable to or higher than the rate in the controlled trials. The intervention was also associated with increased cessation among those who smoked, as well as an ancillary increase in household smokefree vehicle policies.

A study by Eakin and colleagues (2014) also focused on creating smokefree homes rather than on smoking cessation by testing the effectiveness of an intervention that included motivational interviews and education versus education alone (control). Study participants included the caregivers of 350 children enrolled in Head Start programs in Baltimore, Maryland, who reported that a person who smoked lived in the home. All participants earned lower incomes, and participants were predominantly African American. The intervention consisted of up to five counseling sessions over three months that focused on motivating and assisting the participant to reduce the child’s exposure to secondhand tobacco smoke through implementing smokefree home rules. Both groups (intervention and control) received general educational materials on smokefree homes from the Environmental Protection Agency. Smokefree home rules increased among both the intervention and control groups. In modeling adjusted for time and to control for correlation of outcomes within individuals and baselines characteristics, participants in the intervention group had significant increases in the prevalence of smokefree home rules, declines in overall air nicotine levels, and declines in smoking among caregivers compared to participants in the control group. Despite the effects of the intervention, no significant differences in children’s salivary cotinine levels were observed at 12-month follow-up, but among those creating a smokefree home in both groups, declines in levels of salivary cotinine were significant.

Prokhorov and colleagues (2013) recruited households of Mexican American people with a child under the age of 18 and two adults, one of whom smoked, for a brief educational intervention on smokefree homes. The educational intervention included one culturally appropriate comic book (available in English and Spanish) for children and two fotonovelas (stories containing abundant pictures and appropriate for low-literacy individuals) for adults. Both resources were designed to increase awareness of the negative impact of secondhand tobacco smoke. Standard care included a copy of a self-help booklet designed to help people quit cigarette smoking. This randomized controlled trial observed significant effects from baseline to 12 months after the intervention in the creation of homes with smokefree rules and levels of airborne nicotine measured in the home. At 12 months, 73% of households that received culturally relevant educational materials had created smokefree home rules compared with 56% of households that received standard care (p <0.001) (all households in both conditions allowed smoking in the home at baseline). Overall, mean air nicotine levels measured in the home declined during this study period. However, a significant interaction (p <0.05) was observed by intervention condition over time, meaning that declines in mean air nicotine levels from baseline to 12 months were greater in households that received culturally relevant educational materials (from 1.14 μg/m^3^ to 0.20 μg/m^3^; p <0.01) than they were in homes in the standard care condition (from 0.55 μg/m^3^ to 0.17 μg/m^3^; p = 0.99).

#### Reducing Exposure to Secondhand Tobacco Smoke in Private Vehicles

As discussed earlier in this chapter, nearly 25% of U.S. high school and middle school students reported being exposed to secondhand tobacco smoke in vehicles in 2019, and most smoking restrictions in vehicles are established through voluntary household rules (Rees and Connolly 2006; Walton et al. 2020).

Parks and colleagues (2020) studied a pilot intervention focused on the adoption of smokefree home and vehicle rules among people with lower incomes who smoked or lived with someone who smoked, and who had at least one child under 18 years of age in the home. All recruited participants were sent three educational mailings and either a coaching email or letter addressing smokefree rules in both homes and cars, focusing specifically on households with children. Among recruited participants who completed the baseline survey (n = 50) with completed follow-up data at 3 months (n = 39) and 6 months (n = 33), statistically significant increases in smokefree rules in homes (from 12.8% at baseline to 69.2% and 63.2% at 3- and 6-month follow-up, respectively) and vehicles (among recruited participants with vehicles; from 7.9% at baseline to 38.5% and 45.5% at 3- and 6-month follow-up, respectively) were observed.

Although not a focus of their intervention, Bundy and colleagues (2020) reported an increase in the adoption of smokefree vehicle rules to be an ancillary benefit of an intervention related to smokefree home rules. Although there is little research directly evaluating the impact of smokefree vehicle rules on reducing health disparities, a strong theoretical basis exists for concluding that this intervention would help protect people who are disproportionately exposed to secondhand tobacco smoke in vehicles (King et al. 2013b; Parks et al. 2018).

#### Summary and Recommendations

This section examined a variety of approaches to reduce exposure to secondhand tobacco smoke among households. There is insufficient evidence to infer that interventions that seek to reduce exposure to secondhand tobacco smoke in the home without the adoption of an accompanying smokefree home rule will reduce tobacco-related disparities. Nonetheless, interventions that increase the prevalence of smokefree home rules have been shown to reach people from population groups that experience disparities in tobacco use and exposure to secondhand tobacco smoke (e.g., people from minoritized racial and ethnic groups, people with lower SES) and interventions that increase the prevalence of smokefree vehicle rules also may reach people experiencing disparities in exposure to secondhand tobacco smoke. The smokefree home studies without significant findings still saw increases in the percentage of smokefree homes in both the intervention and control groups.

The interventions that were most effective consisted of educational materials and motivational interviewing or coaching. Comprehensive state or local smokefree policies for public places have also been shown to increase the prevalence of smokefree homes (Guzman et al. 2012; Monson and Arsenault 2017; Hafez et al. 2019) and reduce exposure to secondhand tobacco smoke in the home (Nanninga et al. 2018, 2019).

Future efforts should employ a three-pronged approach aimed at promoting (1) the voluntary adoption of rules for a smokefree home at the household level; (2) smokefree policies in multi-unit housing, as discussed in detail earlier in this chapter; and (3) comprehensive smokefree policies at the tribal, territorial, state, and local levels. Much of the existing research on voluntary interventions focuses on households with children, and continued efforts to reach these households are warranted. Research is also necessary to inform outreach to households without children. Additional studies on how best to promote smokefree home and vehicle rules, specifically among population groups that are marked by tobacco-related health disparities—including sexual orientation and gender identity groups, certain minoritized racial and ethnic groups, and people who have behavioral health conditions—would aid in further implementation of this strategy.

### Interventions Engaging Dyadic Support for Smoking Cessation

For the purpose of this review, dyadic support includes, but is not limited to, partner, family, or peer support that involves participation from one or more people in a specific intervention component (or components) for smoking cessation. This section addresses (1) the types of interventions for dyadic support in smoking cessation; (2) the effects of the components of dyadic support interventions on smoking cessation; and (3) recommendations and implications for future interventions and policies to address tobacco-related health disparities. Table 7.7 presents details on the 11 studies included in this discussion, including each study’s population, design, location, intervention, and outcomes.

#### Types of Cessation Interventions with Dyadic Support

The following sections describe the components of the dyadic support interventions in the reviewed studies, including what groups were included, recruitment and engagement strategies, and how the interventions engaged the support person.

Table 7.7 Dyadic support intervention studies

Study | Design, population, and location | Intervention arm(s) | Outcomes^a^
McDonnell et al. (2014) | - Single group; - Eight dyads (16 total participants [8 male clinic patients and their 8 female household members]; both persons in dyad smoked; - Clinic patients were persons diagnosed with cancer or with a suspicious thoracic mass scheduled for surgery at a thoracic surgery clinic in a university hospital in Central Virginia; - All participants were Caucasian, and 13 of 16 had annual income <$50,000; - Clinic patients had to be willing to consider stopping smoking to participate; - Setting: Clinical; - Location: Central Virginia | - Duration: 6 months; - Intervention: Each dyad received:; – Brief smoking cessation counseling (3–5 minutes); – Decision-making tutorial (one page, CD, and CD player for home use) and decision balance sheets; – Smoking cessation booklet; – Four face-to-face counseling sessions (approximately 45 minutes each) with an oncology-certified nurse who was trained as a tobacco cessation treatment specialist; – Up to six optional remote booster sessions (<15 minutes each) | - Primary outcome: Continuous abstinence at 6 months post-surgery:; – 63% (five of eight) of patients remained abstinent (CO verified); – 25% (two of eight) of family members were abstinent
Kim et al. (2015) | - Two-arm RCT; - 109 Korean American participants (91 men and 18 women) who smoked ≥10 cigarettes per day, as well as family members of participants in the intervention condition who were invited to participate in therapy sessions; - Participants were adults who smoked at least 10 cigarettes per day for the past 6 months and were willing to use nicotine patches as directed; - Support persons were not required at the time of enrollment. Support persons were family members and could smoke or not smoke. Participants assigned to the intervention were asked to provide permission to contact family members who were invited to participate in all therapy sessions.; - Setting: Community; - Location: Northeast United States, primarily from such Korean-immigrant-dense areas as Queens, New York, and Palisades Park, New Jersey | - Both control and treatment interventions:; – Eight weekly in-person individual counseling sessions; – Choice of receiving interventions in Korean or English language; – Education on the harms of smoking, nicotine dependence and withdrawal, and NRT treatment; – Administration of expired CO test at each session and explanation of results; – A 1-week supply of nicotine patches at each session; – $20 gift certificate at baseline and 1-month follow-up; – $40 gift certificate at 3-month, 6-month, and 12-month follow-up; - Control intervention:; – 10-minute weekly counseling sessions; - Treatment intervention:; – 40-minute weekly counseling sessions; – Receipt of culturally specific components:; - Use of analogy of gas poisoning from coal briquettes used in pre-1990s Korean heating systems to explain harms of CO; - Information about smoking-related cancer deaths among celebrities in Korea, high rates of such deaths among Korean men in California, and harms of exposure to secondhand tobacco smoke; - Coaching family members to provide assistance and support; - Use of Korean news media in education; - Behavioral skills training for Korean-specific relapse-prone situations | - Primary outcome: 12-month prolonged abstinence assessed by self-report and biological confirmation (expired-air CO, <6 ppm) and salivary cotinine (<30 ng/mL):; – Significantly higher among participants who received the treatment intervention (38.2%) than among those in the control intervention (11.1%); – OR = 4.67; 95% CI, 1.67–12.99, p <0.01
LaChance et al. (2015) | - Two-arm RCT; - 49 couples consisting of (a) people who smoked >10 cigarettes per day and who wanted help with quitting smoking and (b) their nonsmoking partners (CO <10 ppm) who were recruited from the community; - Among those participants who smoked, 88% were White, 67% were male, and 26.5% had a college degree or some graduate school education; - People who smoked were willing to use nicotine patches (inclusion criteria); - Support persons were partners who did not smoke (in heterosexual marriage or cohabitating for 1 or more years); - Setting: Community (not specified); - Location: United States, not otherwise specified | - Duration: 7 weeks; - Standard condition:; – Individually delivered behavior therapy for smoking cessation, self-help materi and 8 weeks of NRT patches; - Treatment condition:; – Behavioral couples’ therapy: Seven, 60-minute sessions of social support intervention and 8 weeks of NRT patches; – Couples completed “I Quit Contract” and both signed a written agreement; – Treatment involved role playing and discussing how partners could provide support | - Primary outcome: 7-day point-prevalence self-reported als, abstinence at 6 months, biochemically verified by urinary cotinine (>8 ppm):; – Standard condition: 55%; – Treatment condition: 45%; – p = 0.35
Pollak et al. (2015) | - Two-arm RCT; - 348 dyads: Pregnant Latina women between 13- and 29 weeks gestation who did not smoke and their partners who did smoke; – 68% spoke only Spanish at home; – 66% had <10 years of education; - 39% of people who smoked did so every day, and 61% did so some days; - Intention to quit smoking was not assessed or reported; - Setting: Nonsmoking mothers were recruited from 10 urban and rural county health departments; - Location: North Carolina | - Duration: 6 months or longer, from prenatal (13–29 weeks gestation) to 4 months postpartum; - Standard condition:; – Written materials and NRT (optional, up to 6 weeks); - Treatment condition:; – Community-based partnership with El Centro Hispano to culturally adapt the intervention; – Community advisory panel; – Conducted focus groups with expectant Latino couples; – Written materials, NRT (optional, up to 6 weeks); - Couples-based and individual counseling addressing smoking cessation and communication | - Primary outcome: 7-day point-prevalence abstinence rates at 12 months post-randomization:; – Standard condition: 39%; – Treatment condition: 38%; – No group differences
Tsoh et al. (2015) | - Single-group study; - 96 Chinese and Vietnamese dyads (males who smoked daily and support persons who were nonsmoking family members) who had to read and speak Cantonese, Mandarin, or Vietnamese; – Among males who smoked, 51.1% had annual household incomes <$20,000 and 41.7% had less than a high school education; – People who smoked and were any readiness level to quit could participate; 41.7% of males at baseline had no intention to quit smoking within 6 months; – Support persons were nonsmoking family members living in the same household as participants who smoked.; - Setting: Community; recruited through lay health workers; - Location: California | - Duration: 2 months; - Intervention:; – Dyadic and social network-based intervention consisting of two small-group (ranging from two to four dyads) educational sessions conducted by lay health workers; – Two telephone calls made individually to males who smoked and the family members of participants over 2 months; - $25 each for completing assessment telephone surveys at baseline and at 3 months | - Primary outcomes: 7-day and 30-day point-prevalence abstinence (intent-to-treat analysis) at 3 months (independently verified by family members):; – 7-day point-prevalence abstinence: 30.2%; – 30-day point-prevalence abstinence: 24.0%
Dickerson et al. (2016) | - Single-group study; - 30 people who smoked daily were recruited from psychiatric rehabilitation programs; - Eligibility criteria:; – Diagnosis of schizophrenia, schizoaffective disorder, bipolar disorder, or recurrent major depression; – Worked <25% of the previous year; – Received payment for mental disability; – Were ready to quit smoking within the next 6 months; - Support persons were eight peer mentors who used to smoke and had received treatment for serious mental illness; each peer mentor worked with two participants in each group; - Setting: Clinics and psychiatric rehabilitation programs; research staff recruited people who smoked; - Location: Maryland | - Duration: 6 months; - Intervention:; – Peer mentor program added to a professionally led behavioral group intervention for smoking cessation that was tailored for persons with serious mental illness.; – Groups met twice weekly over 3 months (24 meetings, 1 hour each) and were led by a trained interventionist and two peer mentors who participated on a rotating basis; – Participants received $3.00 for every session they attended; – Nicotine patch was available to interested participants; – Participants had expired CO measured with feedback and monetary reinforcement ($1.50–$3.50 for CO <8 ppm); – Peer mentors received 22 hours of training and ongoing group supervision; – Peer mentors met one-on-one in person and by telephone for 1–2 hours weekly for 6 months with people who smoked. | - Primary outcomes:; – 73% of participants (22 of 30) made a quit attempt; – 7-day point-prevalence sustained abstinence was 10% (abstained for at least 7 days and remained quit at the final study visit with biochemical verification [urinary or expired cotinine])
Kim (2017) | - Single-group study; - 31 Korean American people who smoked ≥10 cigarettes per day and support persons who were family members were invited to participate; 94% of the sample was male; – People who smoked were ready to quit smoking within 30 days (inclusion criteria); – Support persons were not required at the time of enrollment; at the first session, people who smoked provided permission to counselors to contact family members and invite them to join subsequent sessions; - Setting: Community; people who smoked were recruited through Korean-speaking radio station; - Location: New York City | - Duration: 8 weeks; - Intervention:; – Eight weekly telephone-based cessation counseling sessions and 4 weeks of nicotine patches; – First session lasted 30–40 minutes; subsequent sessions lasted 10–15 minutes; – Family members were coached to provide assistance and support and were invited or called into counseling sessions (before and after quit day; not specified if this took place with or without participant) | - Primary outcomes (intent-to-treat analysis):; – 7-day point-prevalence abstinence at 3 months: 45.2%; – 3-month prolonged abstinence: 41.9%; – Family members corroborated self-reports, except those from two participants who lived alone
Tsoh et al. (2017) | - Two-arm cluster RCT; - 107 Vietnamese dyads consisting of males who smoked and family members who did not smoke; – 40.7% of the males who smoked daily had less than a high school education; – Males who smoked and were at all levels of readiness for quitting smoking could participate; 26.2% had no intention to quit within 6 months at baseline.; – Dyadic pair was family member who did not smoke; - Setting: Community; recruited by lay health workers; - Location: California | - Duration: 8 weeks; - Intervention:; – Dyadic and social network-based intervention was delivered by lay health workers and consisted of two small-group educational sessions that focused on tobacco cessation and included two telephone calls made individually to participants (people of who smoked and their family members) over 8 weeks; – Participants received information about smoking cessation resources; - Comparison:; – Same format as intervention but focused on healthy living (nutrition, physical activity); – Participants did not receive information about smoking cessation resources until 6 months after the end of the study | - Primary outcome: 30-day point-prevalence abstinence at 6 months verified by family and salivary cotinine:; – Comparison condition: 12.5%; – Intervention condition: 33.3%; – OR = 3.7; 95% CI, 1.2–11.5
Tong et al. (2018a) | - Two-arm RCT; - 203 participant pairs (Cantonese-speaking Chinese American males who smoked and family members who did not smoke); - Males who smoked and were at all levels of readiness for quitting smoking could participate; 54.2% intended to quit within 6 months; 23.6% of males did not smoke daily; - Support persons did not smoke and were household members of the male participants who did smoke:; – 90% of study sample were spouses; – 10% were parent-child dyads; - Setting: Community; research staff recruited either a partner or a male who smoked, who in turn provided permission for the research staff to contact the other potential family member to form a person who smoked-household member dyad to participate in the study; - Location: San Francisco, California | - Duration: 6 months; - Brief intensity group: One group educational session (1 hour); - Moderate-intensity group:; – Two dyadic educational sessions (90 minutes over 3 months) to discuss exposure to secondhand tobacco smoke and cessation resources and review lab results of baseline exposure to tobacco smoke, plus two or three individual follow-up calls (<15 minutes) over 6 months; – Bilingual booklet that summarized educational materials; - All received up to $60 for completion of assessments | - Primary outcome: 30-day abstinence at 12 months biochemically verified (urinary NNAL/Cr <40 pg/mg):; – Brief condition: 20.0%; – Moderate intensity condition: 20.7%; – No group differences
Ruebush et al. (2020) | - Single-group pilot study; - 532 patients who received tobacco use treatment through the University of North Carolina Tobacco Treatment Program at the North Carolina Cancer Hospital; - Most patients were White (69.2%) or African American (22.7%) people; - Integrated family members were typically spouses or partners but were occasionally adult children, siblings, parents, or close friends of patients; - Program included family members who did and did not use tobacco; - Setting: Clinical; recruited through the University of North Carolina Tobacco Treatment Program (referred by medical providers in any department) at the North Carolina Cancer Hospital; - Location: North Carolina | - Duration: Study lasted 18 months; on average patients received 1.5 tobacco use treatment sessions; - Intervention: Implementation of family counseling for tobacco use treatment included four phases: (1) modifying the electronic health record and its monthly report; (2) training tobacco treatment specialists to provide family counseling; (3) integrating family members into patients’ treatment, and (4) conducting 6-month follow-up calls; - 221 patients (42%) had family members integrated into their tobacco use treatment; 21 patients (4%) had family members present but not integrated; and family members were not present for the remaining patients | - Primary outcome: Intent-to-treat quit rates at 6 months following their initial session were based on self-reported, 7-day point-prevalence abstinence:; – 28% among patients whose family members were integrated; – 23% among patients whose family members were not integrated (p = 0.105)
Haskins et al. (2022) | - Single-group feasibility study; - Testing feasibility of adapting a financial incentive treatment to a dyadic context; although not designed to test intervention efficacy, cessation outcomes were examined for descriptive purposes; - 28 adults (14 couple dyads) who currently smoked >5 cigarettes per day or >100 cigarettes in the lifetime and were cohabiting for >6 months with a romantic partner who currently smoked; - Setting: Community; recruited via flyers and social media ads; - Location: Athens, Georgia | - Duration: 4 weeks; - Intervention:; – Pfizer, Inc’s Beat the Pack smoking cessation program; – One session per week for 4 weeks; – Each participant could receive (a) $100 for attending all four sessions or $75 for attending three of four sessions and (b) $100 for abstinence at 1-month follow-up (7-day point-prevalence with biochemical verification [CO, 5 ppm]); – All had the option to receive free NRT; – Received $30 for baseline completion and $25 for follow-up completion; – Received a $20 bonus each for both partners completing baseline and follow-up | - Primary outcome: Intent-to-treat, biochemically verified smoking abstinence:; – 25% at 1-month follow-up; – Six of the seven abstinent participants (86%, OR = 6.14) were members of dyads in which both members were abstinent

Notes: CD = compact disc; CI = confidence interval; CO = carbon monoxide; mL = milliliter; ng = nanogram; NNAL/Cr = 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanol/creatinine; NRT = nicotine replacement therapy; OR = odds ratio; pg = picogram; ppm = parts per million; RCT = randomized controlled trial.

a Rates of smoking abstinence were biochemically verified by CO or salivary cotinine or by corroboration of a family member.

##### Focus Population Groups

A variety of focus population groups were included among the reviewed studies, and most of these studies focused on tobacco use among Asian American adults while one study focused on Mexican American people (Pollak et al. 2015). The Asian American population groups included Korean American (Kim et al. 2015; Kim 2017), Chinese American (Tsoh et al. 2015; Kim 2017; Tong et al. 2018a), and Vietnamese American (Tsoh et al. 2015, 2017) people. Members of these priority populations are sometimes immigrants with limited English proficiency. In addition, the prevalence of smoking is often high among members of these groups, and the acceptability of smoking is often high among men in their countries of origin (see the “Acculturation” section in Chapter 4). For example, U.S. studies designed to reach Korean American or Vietnamese American people have reported high rates of smoking among men when they lived in Korea or Vietnam, respectively (Drope et al. 2018). Many of the interventions included in this review emphasized smoking cessation for the male partner in the dyad; some also addressed the elimination of exposure to secondhand tobacco smoke (Tong et al. 2018a). The studies designed to reach Asian American people were concentrated in areas of the United States with a high proportion of Asian American ethnic population groups—specifically California, New York, and New Jersey.

##### Recruitment and Engagement

One challenge in addressing tobacco use in priority populations is the recruitment and engagement of people from diverse populations in which access to smoking cessation resources is limited and the prevalence of smoking remains high. Studies of dyadic support interventions have used various recruitment approaches, including a conventional approach in which people who smoke are recruited directly with or without a requirement to include a support person and approaches that target the person who will provide cessation or social support to the person who smokes. In many cases, recruitment or eligibility was also contingent on the participants’ willingness to quit smoking, which may affect the outcomes of smoking cessation in dyadic support interventions.

Seven of the reviewed studies recruited participants from community settings (Kim et al. 2015, 2017; Pollak et al. 2015; Tsoh et al. 2015, 2017; Tong et al. 2018a; Haskins et al. 2022). Three studies focused on clinical populations; in one of these studies, adult participants were recruited from psychiatric rehabilitation programs (Dickerson et al. 2016) and two studies recruited participants from oncology clinical settings (McDonnell et al. 2014; Ruebush et al. 2020). Finally, one study recruited adult participants via newspaper and television advertisements (87.8% of enrolled people who smoked were White and 26.5% were college graduates) (LaChance et al. 2015).

Four of the 11 studies reviewed in Table 7.7 used a recruitment strategy that first identified the support person of a person who smokes (Pollak et al. 2015; Tsoh et al. 2015, 2017; Tong et al. 2018a); the person who smokes did not have to be motivated to quit to participate in the trial. The remaining seven studies recruited people who smoke who were willing to quit smoking (McDonnell et al. 2014; Kim et al. 2015, 2017; LaChance et al. 2015; Dickerson et al. 2016; Ruebush et al. 2020; Haskins et al. 2022).

##### Engagement of the Support Person

The support person in the reviewed studies participated in various ways in the interventions, most often through in-person participation in dyadic sessions with the person who smokes, and/or in individual training or counseling sessions without the person who smokes. In seven of the studies, the support person was required to participate with the person who smokes in dyadic counseling sessions (McDonnell et al. 2014; LaChance et al. 2015; Pollak et al. 2015), educational group meetings (Tsoh et al. 2015, 2017; Tong et al. 2018a), or a combination of group counseling and one-on-one support sessions (Dickerson et al. 2016). Four of the studies invited the family member of the person who smokes to join one or more counseling sessions, but participation was optional (Kim et al. 2015, 2017; Ruebush et al. 2020; Haskins et al. 2022).

#### Effects of Dyadic Support Intervention Components

The discussion of abstinence outcomes in Table 7.7 is organized by study design and the intention of the people who smoke to quit at pre-intervention. Nine of the 11 studies included in this review reported abstinence rates that were biochemically verified by expired carbon monoxide, salivary cotinine, or independent corroboration by another person (e.g., a family member). For studies with multiple time points, abstinence rates reported in Table 7.7 represent the latest available time point (6, 9, or 12 months) using 30-day point-prevalence abstinence or, if not available, 7-day point-prevalence abstinence as the outcome; data are reported in the summary that follows.

##### Smoking Abstinence Outcomes by Study Design

The 7-day or 30-day point-prevalence abstinence rates at 6 or 12 months for participants receiving dyadic support interventions ranged from 20.7% among adults who smoke who were at any level of readiness to quit (Tong et al. 2018a) to 63.0% among adults who smoke and had cancer who were recruited through thoracic surgery units and who were willing to stop smoking before surgery (McDonnell et al. 2014).

Among the five RCTs in this review, two trials found significant treatment differences in smoking abstinence at follow-up (Kim et al. 2015; Tsoh et al. 2017; Janice Tsoh, University of California–San Francisco, personal communication, July 11, 2021). Both these trials focused on non-English-speaking Asian American people. In one of these two trials, which reached Korean American men and women who smoke (Kim et al. 2015), the 7-day point-prevalence abstinence rates at 12-month follow-up were 42% (intervention) and 19% (comparison). In the second of these RCTs, which included Vietnamese American people who smoke daily and their family member, the 30-day point-prevalence abstinence rates at 6 months were 33.3% (intervention) and 12.5% (comparison) (Tsoh et al. 2017).

##### Smoking Abstinence Outcomes by Intention to Quit

Five of the 11 studies in this review—including two RCTs (Kim et al. 2015; LaChance et al. 2015) and three single-group trials (McDonnell et al. 2014; Dickerson et al. 2016; Kim 2017)—required adults who smoke to be willing to quit smoking. The studies generally reported high rates of abstinence among adults who smoke who were ready to quit smoking, except for a study that focused on adults who smoke with serious mental illness, which reported an abstinence rate of just 10% at the 6-month follow-up (Dickerson et al. 2016). One of the two RCTs (Kim et al. 2015) showed a statistically significant dyadic support treatment effect (42% in intervention vs. 19% in comparison) for Korean American adults who smoke, whereas the remaining two single-group trials of men reported abstinence rates of 45% (Kim 2017) and 63% (McDonnell et al. 2014).

The remaining six trials in this review did not require people who smoke to be motivated to quit to enroll in the study (Pollak et al. 2015; Tsoh et al. 2015, 2017; Tong et al. 2018a; Ruebush et al. 2020; Haskins et al. 2022). One of the RCTs examining Vietnamese American dyads (person who smoked with family member) in community settings detected group differences in the 30-day point-prevalence abstinence rate between the intervention and comparison groups (33.0% vs. 12.7%) at 6 months (Tsoh et al. 2017). Notably, two RCTs included people who smoke daily and nondaily; both types of smoking are prevalent in the targeted communities of Latino and Chinese American people (Pollak et al. 2015; Tong et al. 2018a). In these studies, rates of abstinence were similar among both people who smoked daily and nondaily in the intervention and control groups. In the remaining single-group trials, one included Chinese and Vietnamese adults who smoked (Tsoh et al. 2015); the 42% of adults who smoked who were not ready to quit smoking had a 30-day abstinence rate of 24% at the 3-month follow-up. The other two studies did not report abstinence by readiness to quit (Ruebush et al. 2020; Haskins et al. 2022).

Reported abstinence rates were generally higher in studies that focused on people who smoke and were motivated to quit compared with studies in which people who smoke were not ready to quit. In summary, offering a dyadic component in tobacco cessation treatment has the potential to engage people who smoke who are less ready to quit smoking or otherwise would not seek treatment for smoking cessation. Nonetheless, the evidence regarding the potential benefit of dyadic support in enhancing quit rates remains inconclusive when compared with interventions that do not have a dyadic component. Further, there was no evidence that inclusion of a dyadic support component negatively affected abstinence rates despite the relatively low abstinence rates seen in some of these trials.

#### Summary and Recommendations

The results from the studies in this review suggest wide variability in the effects of dyadic support-based smoking cessation interventions. A 2018 Cochrane review on partner support and smoking cessation included 14 trials from qualified RCTs published between 1986 and 2016 (Faseru et al. 2018) and concluded that the evidence from RCTs to date had failed to show a beneficial impact of partner-support–based interventions on long-term smoking abstinence; however, that review did not report outcomes for groups affected by disparities in tobacco use prevalence or cessation, including minoritized racial and ethnic groups, lower income groups, or members of minoritized sexual orientation and gender identity groups.

The studies reviewed here suggest that dyadic interventions may have a beneficial impact on smoking cessation for Asian American people who smoke, although larger studies are needed to determine program effectiveness. Importantly, Faseru and colleagues (2018) observed that variability in intervention components contributed to the meta-analytic challenges in examining the benefit of partner-support-based tobacco cessation treatment.

The inclusion of a dyadic support intervention component has shown promise in engaging Asian American people who smoke, as well as people who smoke who are not motivated to quit. This may be attributable, in part, to messages regarding family health having potentially increased resonance with some of these population groups. For example, in a focus group study of Chinese American dyads made up of adults who smoke and adults who do not smoke who had participated in a dyadic cessation intervention, participants shared a preference for dyadic and group interventions. The study noted that the inclusion of adults who do not smoke in the dyadic intervention appeared to empower them to support those who smoke in cessation and improve support for smokefree living (Saw et al. 2018a).

To confirm study findings, future research on dyadic interventions and other family systems-oriented approaches for smoking cessation needs to include larger numbers of participants for population groups in which these strategies have already been tested. Dyadic interventions also need to be evaluated for other priority populations who bear disproportionate tobacco-related health disparities, including American Indian and Alaska Native people, Native Hawaiian and Pacific Island people, Black or African American people, people with lower SES, and members of minoritized sexual orientation and gender identity groups. More evaluation is also needed among Hispanic or Latino people because only one study was conducted among this group and Pollak and colleagues (2015) observed no change in cessation rates when a dyadic intervention was added to written materials and NRT. In addition, because dyadic support may take multiple forms, resource availability and the feasibility and cultural sensitivity of such interventions should be considered carefully in intervention design.

## Individual-Level Interventions

Individual-level interventions for tobacco cessation are an important component of comprehensive tobacco control efforts. As summarized in the 2020 Surgeon General’s report on smoking cessation, current evidence-based treatment approaches to smoking cessation include behavioral treatments—such as individual, group, and telephone counseling—and seven pharmacotherapies approved by the FDA (USDHHS 2020). Although these interventions are effective when used independently, evidence indicates that the combined use of behavioral and pharmacologic treatments produces the largest cessation effects (USDHHS 2020).

Current clinical practice guidelines from the U.S. Public Health Service recommend use of evidence-based treatments “for all individuals who use tobacco, except when medication use is contraindicated or with specific populations [such as pregnant women] in which medication has not been shown to be effective” (Fiore et al. 2008, p. 143). This clinical recommendation was based on three factors: (1) several of the RCTs reviewed for the guideline included diverse samples; (2) studies testing interventions in specific populations demonstrated effectiveness; and (3) the balance of “the relative safety of the tobacco dependence treatments versus the hazards of continued tobacco use” (Fiore et al. 2008, p. 144). More research is needed to identify cessation treatments and treatment components that may be especially effective, or may enhance the effectiveness of treatments, for groups experiencing disparities in tobacco use and cessation. It is important to contextualize individual treatment approaches within social and structural determinants of health, including access to healthcare. Cessation treatment access and healthcare coverage are addressed earlier in this chapter.

This section summarizes and evaluates evidence regarding the effectiveness of individual-level cessation interventions for specific populations, with a particular emphasis on whether tailored or enhanced interventions increase effectiveness compared with usual care for populations that have higher levels of tobacco use, lower levels of tobacco cessation, lower levels of utilization of effective cessation treatments, and/or tobacco-related health disparities. For most of the studies included in this review, “usual care” included proven cessation treatments that were not tailored (Fiore et al. 2008), whereas in some studies “usual care” included self-help materials and information on accessing quitlines and other services.

The scientific review focuses primarily on tailored interventions among U.S. populations that are characterized by SES, race and ethnicity, sexual orientation and gender identity, and geography (such as rural populations). Research regarding individual-level interventions focused on other populations who experience disparities (e.g., adolescents, people with mental health conditions) is detailed in the 2020 Surgeon General’s report (USDHHS 2020). Clinical delivery of individual-level interventions is reviewed in the “Healthcare System Interventions” section of this chapter. Cessation interventions delivered via quitlines, including through digital technologies, are reviewed in the “Tobacco Quitlines” section of this chapter.

The present review includes findings from RCTs with sufficient sample sizes to draw population-level inferences about the scalability of the intervention. The primary outcomes related to quitting are reported. If available, abstinence rates are reported based on intent-to-treat analysis, which assumes that those lost to follow-up continued smoking. This section also discusses the implications of the reported findings as they relate to understanding or reducing tobacco-related health disparities for groups marked by disparities. Studies focused on adolescent patient samples were excluded. The section concludes with a discussion about the scalability of the interventions examined, the potential for research on intervention implementation, promising intervention approaches, and gaps in the literature.

### Groups with Lower Socioeconomic Status

Levels of income and education are common indicators of SES, and tobacco smoking is inversely associated with both these measures (Creamer et al. 2019). Both the prevalence of past-year quit attempts and successful cessation tend to increase with increasing levels of education (USDHHS 2020). Because the diverse group of people with lower SES may have fewer resources or less access to evidence-based treatments than those with higher SES, interventions should be designed or chosen with careful consideration given to their acceptability, potential reach, and impact. Four meta-analyses examined the effectiveness of individual-level cessation interventions among people with lower SES (Fiore et al. 2008; Bryant et al. 2011; Hill et al. 2014; Kock et al. 2019).

The Clinical Practice Guideline included a meta-analysis of five RCTs comparing counseling with usual care or no counseling among people of lower SES and/or with limited formal education (Fiore et al. 2008). Results from the meta-analysis showed that counseling was effective in treating people with lower SES who smoke (OR = 1.42; 95% CI, 1.04–1.92; abstinence rate without counseling = 13.2%, with counseling = 17.7%) (Fiore et al. 2008). Interventions in the five studies included: (1) motivational messages with and without telephone counseling for lower income mothers and lower income African American people; (2) proactive telephone counseling in addition to nicotine patches; and (3) tailored bedside counseling and follow-up for hospitalized African American patients (Fiore et al. 2008).

Bryant and colleagues (2011), in their meta-analysis of three studies among lower income women attending pediatric or Planned Parenthood clinics, found a significant effect of a multicomponent motivational interviewing intervention compared with usual care or brief advice at 6–12 weeks follow-up (relative risk [RR] = 1.68; 95% CI, 1.21–2.33) but not at their longest follow-up point, which varied across the studies (RR = 1.28; 95% CI, 0.96–1.72). In addition, three interventions sought to reach pregnant women with lower incomes; no effect for behavioral cessation interventions compared with usual care or brief intervention was observed at their third trimester or at their 6-month postpartum follow-up.

Bryant and colleagues (2011) also conducted a meta-analysis of four behavioral support cessation interventions designed to reach people with lower incomes who were living in deprived neighborhoods or attending public health clinics and found no significant effects for short-term (RR = 1.87; 95% CI, 0.91–3.83) or long-term (RR = 1.58; 95% CI, 0.79–3.14) cessation outcomes. Two other studies in their review found significant effects of behavioral interventions compared with a control group for people with lower incomes; one study compared a self-help cognitive behavioral therapy (CBT) cessation program with educational materials, and another compared brief advice from dental practitioners using the 5 A’s and NRT with usual care.

Hill and colleagues (2014) reviewed 20 studies of combined behavioral counseling and cessation medication interventions that either examined the impact of cessation services by SES or were directed to lower SES population groups; they included both RCTs and observational studies in their review. Among the nine studies using combined behavioral and pharmacologic interventions that examined the impact by SES, lower quit rates were observed among lower SES people who smoke compared with those with higher SES in most studies; however, no differences in quit rates by SES were observed in two inpatient studies. Similarly, their review of cessation programs that contained only behavioral interventions found lower cessation among participants with lower SES compared with those with higher SES. Their review of 11 studies that examined cessation programs designed to reach people with lower SES who smoke found mixed results, with some producing generally low quit rates and others producing higher quit rates (Hill et al. 2014). The authors noted that a small number of studies in their review demonstrated greater effectiveness for lower income populations when cessation support was concentrated in less advantaged communities, suggesting targeted services may have a role to play in reducing cessation-related disparities in this population.

A recent systematic review and meta-regression analysis by Kock and colleagues (2019) assessed whether behavioral smoking cessation interventions tailored for lower SES population groups (defined by income, eligibility for government assistance, occupation, and housing) were more effective for cessation compared with nontailored interventions for people with lower SES. This review included 42 RCTs with smoking cessation outcomes 6 or more months from the start of the intervention, 30 of which were in the United States; 26 of the 42 studies were interventions tailored for people with lower SES and 16 were nontailored interventions. Seventeen of the tailored interventions used in-person or telephone counseling, four were digital, three involved financial incentives, and two were brief interventions. Kock and colleagues’ (2019) meta-regression demonstrated a positive pooled effect size for cessation interventions; people with lower SES who participated in an intervention (tailored or not) were more likely to quit smoking than those in the control (or usual care) group (RR = 1.56; 95% CI, 1.39–1.75). A subanalysis for tailored interventions versus the control (or usual care) group had a similarly positive pooled effect size (RR = 1.54; 95% CI, 1.37–1.72). However, Kock and colleagues (2019) found that tailored interventions were not more effective for cessation among people with lower SES compared with nontailored interventions (RR = 1.01; 95% CI, 0.81–1.27). Based on their findings, Kock and colleagues (2019) concluded that, while individual-level interventions are effective at assisting people with lower SES in quitting, current tailored programs have not yet improved cessation effectiveness compared with nontailored programs. The authors further suggested that improvements in tailored interventions for people with lower SES, including multifaceted approaches that address the wider social context of cessation in this population group, should be considered to achieve equity in cessation outcomes.

The current literature review identified three RCTs that examined smoking cessation interventions among adults with lower SES who smoke (Bock et al. 2014; Bernstein et al. 2015; Vidrine et al. 2016) that were not included in the review by Kock and colleagues (2019) because they did not report differential effects by SES. The current review also identified four RCTs (Danan et al. 2018; Alaniz et al. 2019; Dahne et al. 2020b; Rogers et al. 2022a) published after the review by Kock and colleagues (2019) (Table 7.8). Studies focused on testing the effect of financial incentives on cessation are not included here but are summarized later in this section. In addition, some studies summarized in later sections in this chapter on selected racial and ethnic groups also contain primarily lower SES population groups but are not included here (see, in particular, Nollen et al. 2007; Borrelli et al. 2010; Froelicher et al. 2010; Webb et al. 2010a; Cherrington et al. 2015; Rodriguez Esquivel et al. 2015; Webb Hooper et al. 2017a, 2021; Simmons et al. 2022)].

Six of the seven studies included in this review involved patient populations (Rogers and colleagues [2022a] also recruited from the community), and five of the RCTs were delivered in clinics (four were multicomponent and one was a pharmacologic intervention). In one of the five clinic-based studies, Bernstein and colleagues (2015) randomized adults with lower incomes who smoke who came to the emergency department to receive either a self-help quit smoking brochure (i.e., usual care) or a multicomponent intervention (i.e., enhanced care) that included behavioral counseling (i.e., motivational interviewing), 6 weeks of NRT, a proactive referral to a quitline for telephone counseling, and a booster counseling call following discharge. Findings from this study revealed that at 3 months, biochemically verified abstinence was significantly greater in the intervention group than it was in the control group (12.2% vs. 4.9%; OR = 2.72; 95% CI, 1.55–4.75), as was quitline utilization (32.0% vs. 18.7%). Abstinence rates did not differ significantly at 1-year follow-up; however, rates were 16.3% in the intervention group and 11.7% in control group (OR = 1.47; 95% CI, 0.97–2.23). The analysis was not able to detect which intervention components were most effective.

Bock and colleagues (2014) conducted an outpatient cessation trial in southern New England metropolitan areas among racially diverse lower income adults who smoke and found no benefit from adding a motivational enhancement component consisting of individual counseling based on motivational interviewing techniques, compared with usual care. Although multicomponent interventions have feasibility in terms of reaching lower SES people who smoke, they require considerable allocation of clinical resources as well as hiring a dedicated interventionist. Further, the scalability and sustainability of a multicomponent smoking cessation intervention may not be generalizable to the real world of busy, resource-constrained healthcare settings in the United States.

Vidrine and colleagues (2016) recruited adults who smoke via local print media in Houston, Texas; 57% of participants had a total household income of less than $30,000. Participants were randomized to either usual care (four individual sessions based on Fiore et al. 2008), CBT (eight 2-hour in-person group counseling sessions), or mindfulness-based addiction treatment (MBAT) (eight 2-hour in-person group counseling sessions), with all groups given self-help materials and 6 weeks of nicotine patch therapy. The authors observed no treatment effects at 4 or 26 weeks post-quit date. However, MBAT was positively associated with 26-week abstinence among those who were smoking at 4 weeks post-quit date compared with those in usual care (OR = 4.82; 95% CI, 1.25–118.57). The authors concluded that MBAT may promote recovery from early lapses; however, they stated that more research is needed to replicate this finding and to identify underlying mechanisms.

Rogers and colleagues (2022a) randomized adult New York City residents recruited from two safety-net medical centers or the community to either the control intervention of up to nine sessions of individual counseling (first two completed in clinic, the remainder in clinic or at home) and 4 weeks of free NRT or the treatment intervention, which included the control treatment plus financial coaching components integrated into the cessation coaching sessions. At 6-month follow-up, self-reported 7-day point-prevalence abstinence was higher in the intervention group (17%) than in the control group (9.0%) (OR = 2.0; 95% CI, 1.1–3.6), indicating that intervening on the socioeconomic challenges—that is, adding a financial coaching component to individual counseling—may improve smoking cessation outcomes for adults with lower incomes.

Table 7.8 Individual-level tobacco cessation treatment trials among people of lower socioeconomic status who smoke

Study | Design, population, and location | Intervention | Smoking cessation outcomes | Tailoring to the population and study limitations
Bock et al. (2014) | - RCT; - Lower income adults who smoked and were on Medicaid or uninsured (n = 846); - Inner-city hospital-based primary care outpatient clinics; - Primary quit-smoking outcomes measured:; – Biochemically verified 7-day point-prevalence abstinence at 1, 2, 6, and 12 months following baseline; - Southern New England | - Condition 1, standard care (n = 440): Brief physician advice (including four of the 5 A’s: Ask, Advise, Assess, Assist), NRT (patches, 4 weeks), and self-help brochure on quitting smoking; - Condition 2, motivational enhancement (n = 406): All components of standard care group plus 45-minute individual counseling session based on motivational interviewing techniques, the delivery of the fifth “A” (Arrange) at follow-up by a health educator, and two proactive counseling calls | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking): After controlling for selection bias due to high attrition and stratifying participants by last follow-up visit attended, no significant differences were found in the longitudinal trajectories of abstinence rates by condition; - 7-day point-prevalence abstinence rates by follow-up:; – 1-month follow-up:; - Condition 1 = 40% quit; - Condition 2 = 37% quit; - 2-month follow-up:; - Condition 1 = 33% quit; - Condition 2= 32% quit; - 6-month follow-up:; - Condition 1 = 20% quit; - Condition 2 = 24% quit; - 12-month follow-up:; - Condition 1 = 28% quit; - Condition 2 = 29% quit; - After accounting for covariates, hazard rate analysis did not show direct benefit of and any statistically significant increase in abstinence rates due to motivational enhancement intervention (OR = 0.97; 95% CI, 0.36–2.64; p = 0.95); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Adding a motivational enhancement component to an intervention with physician advice and free NRT did not improve abstinence rates for people of low income who smoked | - Tailoring:; – Equivalent translation of materials for English and Spanish speakers; – Counseling available in Spanish and English languages; – Acculturation level assessed; - Limitations:; – Selection bias due to high attrition after randomization; – People who smoked and were in minoritized racial and ethnic groups had a significantly higher level of attrition than people who smoked and were not in these groups; – Acculturated Hispanic people were the most likely participants to drop out of the study
Bernstein et al. (2015) | - RCT; - Adults of lower income who smoked (n = 778) and who had Medicaid or no insurance; - Adults who smoked were recruited from an ED at an urban hospital; - Primary quit-smoking outcomes measured:; – Biochemically verified smoking status at 3 months and 1 year; – Quitline use; - Connecticut | - Condition 1, usual care: Self-help brochure on quitting and information on how to contact the state quitline for counseling support; - Condition 2, enhanced treatment: Motivational interview, a booster call 3 days after ED visit, NRT (6 weeks of patches and gum), proactive referral to quitline, and self-help brochure on quitting; - All subjects received a $10 gift card for enrollment and $25 payments at 1-, 3-, and 12-month follow-up; those who reported abstinence at 3-months received $100 for providing biochemical verification of abstinence | - At 3 months, biochemically confirmed abstinence rates were significantly higher in the enhanced treatment group (12.2%) than they were in the usual care group (4.9%) (OR = 2.72; 95% CI, 1.55–4.75; p <0.001); - At 1 year, self-reported abstinence rates in the enhanced treatment (16.3%) and usual care groups (11.7%) were not significantly different (OR = 1.47; 95% CI, 0.97–2.23); - No differences were observed in effects between Hispanic, White, and African American participants in the enhanced treatment group; - Quitline use was significantly greater in the enhanced treatment group (32.0%) than it was in the usual care group (18.7%) (OR = 2.04; 95% CI, 1.46–2.84); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Motivational-based behavioral counseling showed short-term benefits on smoking cessation (at 3 months) but did not support longer term cessation | - Tailoring:; – No specific tailoring identified; - Limitations:; – Study was not designed or powered to detect a difference in tobacco use at 1-year follow-up; – Study was implemented at a single site; findings might not generalize to other settings; – Used dedicated non-clinical personnel, which may not be feasible in real-world EDs
Vidrine et al. (2016) | - RCT; - Adults who currently smoked (>5 cigarettes per day, expired air CO level >8 ppm) were recruited from Houston via local print media (n = 412); - Diverse population by socioeconomic status: 57.6% had a yearly income <$30,000; - Primary quit-smoking outcomes measured:; – 7-day point-prevalence abstinence was assessed at 4 weeks (biochemically confirmed by CO <6 ppm) and 26 weeks after the quit day (CO <6 ppm or salivary cotinine <20 ng/ml); – Recovery from a lapse among those smoking at 4 weeks: 7-day point-prevalence at 26 weeks (CO <6 ppm); - Houston, Texas | - Condition 1, usual care: Four, 5- to 10-minute individual counseling sessions based on Fiore and colleagues (2008); - Condition 2: CBT delivered in eight, 2-hour, in-person group counseling sessions; - Condition 3: MBAT delivered in eight, 2-hour, in-person group counseling sessions; - All groups received self-help materials and 6 weeks of nicotine patch therapy | - Intent-to-treat analysis; - 7-day point-prevalence abstinence at 4 weeks:; – Usual care: 24.3%; – CBT: 32.3%; – MBAT: 34.4%; - 7-day point-prevalence abstinence at 26 weeks:; – Usual care: 11.7%; – CBT: 15.5%; – MBAT: 13.0%; - Logistic random effects model analysis that compared the efficacy of usual care, CBT, and MBAT over time yielded no significant treatment effects (p = 0.407); - Analyses comparing usual care and MBAT over time indicated no difference (OR = 1.58; 95% CI, 0.84–2.99; p = 0.159); - Among those smoking at 4 weeks, 0% in usual care, 5.0% in CBT, and 10.3% in MBAT were abstinent at 26 weeks; - MBAT facilitated recovery from lapse better than usual care (OR = 4.82; 95% CI, 1.25–118.57; p = 0.023); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Despite no overall significant effects of treatment on abstinence, MBAT may be more effective than usual care in promoting recovery from lapses | - Tailoring:; – MBAT; - Limitations:; – MBAT requires specialized and intensive training on the part of therapists and high levels of individual engagement; therefore, it is not likely to be broadly disseminated in the tested form; – Treatment diffusion bias might have occurred in that two therapists differed both treatments; – Data on intervention fidelity was not collected; – Rates of meditation practice as part of MBAT were low; – Information on patch use was not collected; – Definition of lapse recovery included those who may have never quit and those who achieved some period of abstinence; – Participant attrition was significant
Danan et al. (2018) | - Secondary analysis of RCT; - 5,123 participants were eligible and randomized:; – Adults who currently smoked were identified using electronic medical records from the VA; – 2,565 reported their level of education; – 2,430 reported their level of income; - Primary quit-smoking outcomes measured:; – Self-reported, 6-month prolonged abstinence at 1-year follow-up | - Usual care: Access to smoking cessation service through their local VA and state telephone quitline; - Proactive care: Active recruitment strategy included proactive outreach (mailed materials followed by telephone outreach) with an offer of telephone smoking cessation counseling or referral to in-person counseling | - No interaction between education (p = 0.07) or income (p = 0.74) and treatment arm for 6-month prolonged abstinence; - People who smoked at each level of education and income had higher observed abstinence rates in the proactive care versus usual care; - In individual population group analyses, proactive care had the largest effect size among people who smoked in (a) the lowest education category (<11th grade), with a quit rate of 17.3% compared with 5.7% among those receiving usual care (OR = 3.5; 95% CI, 1.4–8.6); and (b) the lowest income category (<$10,000), with a quit rate of 18.7% compared with 9.4% among those receiving usual care (OR = 2.2; 95% CI, 1.2–4.0); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Compared with usual care, proactive outreach was associated with higher rates of prolonged abstinence for all levels of socioeconomic status; – Proactive outreach interventions that integrate telephone-based care and facilitate cessation medication access have the potential to reduce socioeconomic disparities in quitting smoking | - Tailoring:; – No specific tailoring identified; - Limitations:; – Self-reported measure of prolonged abstinence may be subject to social desirability bias; – Interaction tests may be underpowered, and the original trial was not designed to detect population group effects by level of socioeconomic status; – Population of mostly male U.S. veterans limits generalizability to female veterans and non-veterans
Alaniz et al. (2019) | - RCT; - Lower income pregnant women, ≥13 years of age (n = 185); - Programs, typically county-level health departments, that provide healthcare services to lower income pregnant women; - Primary quit-smoking outcomes measured:; – Biochemically confirmed smoking cessation (i.e., breath CO level <6 ppm) at about 6 months postpartum and self-reported nonsmoking in the previous 7 days (point-prevalence abstinence); - Wisconsin | - Control/Condition 1 (original First Breath program) (n = 94): Cessation counseling during at least two prenatal visits and one postpartum visit, link to Wisconsin Tobacco Quit Line, optional enrollment in a program to receive motivational text messages, one 6-month postpartum in-home abstinence evaluation visit, and the potential to earn $40 in gift cards; - Condition 2 (same as Condition 1 plus additional components) (n = 91): Additional components included one prenatal and three postpartum in-home counseling visits, three postpartum counseling phone calls, and the potential to earn $140 in gift cards | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking): Abstinence rate was 15.5% for women who received postpartum help and 7.4% for women in the control group (p = 0.07); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – The program design benefited from a patient-centric approach, whereby the target population participated in program development, implementation, and redesign | - Tailoring:; – Postpartum support services, such as cessation counseling and guidance about how to be supportive of a new mother, were also provided to others in the household; – Monetary incentives were provided for accepting the postpartum services and for abstinence for the mother; - Limitations:; – Intervention was conducted in community health clinics and may not be generalizable to other clinical settings; – Only 37% of women referred for the program ultimately enrolled; – Abstinence rates fell about 50% from prenatal to 1 month postpartum, with no additional decline through 6 months postpartum, indicating that additional clinical intervention may be necessary to address early relapse
Dahne et al. (2020b) | - Secondary analysis of RCT (randomization was at the clinic level); - 1,245 adults enrolled at 22 primary care clinics; - Recruited English-speaking adults who smoked ≥5 cigarettes per day on ≥25 of the previous 30 days; adults were excluded for FDA contraindications for NRT use (e.g., pregnancy or breast feeding, recent acute cardiovascular event); - Primary quit-smoking outcomes measured:; – Self-reported at 1, 3, and 6-months poststudy; - South Carolina | - Condition 1 (standard care) (n = 652): Take-home bag with basic information about smoking cessation and a brochure with referral to the state quitline; - Condition 2 (standard care and NRT sampling) (n = 593): Same as Condition 1 but take-home bags also included 2-week supplies of nicotine patches (14 mg) and lozenges (4 mg) | - Any medication use:; – The effect of NRT sampling was larger for lower income (<$50,000/year) adults (OR = 7.03; 95% CI, 4.98–9.91) than it was for higher income (>$50,000/year) adults (OR = 3.36; 95% CI, 1.80–6.26) (p = 0.04 for interaction); – NRT sampling increased medication use among adults with at least a high school diploma (OR = 6.61; 95% CI, 4.65–9.36) and those without a high school diploma (OR = 4.66; 95% CI, 3.02–7.18) (p = 0.2 for interaction); - 24-hour quit attempts: The effect of NRT sampling varied by level of income (p = 0.7): Lower income (OR = 1.34; 95% CI, 0.89–2.04) and higher income (OR=0.71; 95% CI, 0.36–1.40); - Any 7-day abstinence: The effect of NRT sampling varied by level of income (p = 0.1): Lower income (OR = 1.59; 95% CI, 0.97–2.59) and higher income (OR = 0.87; 95% CI, 0.39–1.94); - 7-day point-prevalence abstinence at 6-months:; – NRT sampling was associated with cessation among people with lower incomes (OR = 1.97; 95% CI, 1.13–3.42) but not among those with higher income (OR = 0.87; 95% CI, 0.39–1.94) (p = 0.2 for interaction); – NRT sampling increased cessation among those with lower education (OR = 2.23; 95% CI, 1.30–3.82) but not among those with higher education (OR = 0.89; 95% CI, 1.23–3.50) (p = 0.02); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – NRT sampling could narrow cessation disparities by increasing access to medications for people in groups that may have limited access to cessation support | - Tailoring:; – NRT sampling; - Limitations:; – Potential for response bias in results for income because (a) data were missing for 266 participants and (b) other demographics (age, race, and education) of those missing income differed by cessation outcome; – This was a secondary analysis so it was not designed a priori, and it may also be underpowered
Rogers et al. (2022a) | - Randomized waitlist controlled trial; - Adults who had income below 200% of the federal poverty level, spoke English or Spanish, and managed their own funds were recruited from two medical centers and the community (n = 410); - Primary quit-smoking outcomes measured:; – Self-reported 7-day abstinence at 6 months; - New York City | - Control: Up to nine sessions of individual counseling (first two onsite and the remaining sessions either onsite or by telephone), cards to travel by subway to in-person counseling sessions, and a free 4-week supply of NRT; - Intervention: Same as the control group plus financial coaching components were integrated into the cessation coaching sessions, and included screening and referral for financial benefits and empowerment programs and money management coaching | - Intent-to-treat analysis; - At 6 months, abstinence rates were higher among intervention participants than they were among those in the control group (17% vs. 9%; OR = 2.0; 95% CI, 1.1–3.6; p = 0.03); - Abstinence outcomes were stronger among participants recruited from medical centers (20% in intervention and 8% in control) (p = 0.01) than outcomes among those recruited from the community (no treatment difference p >0.05); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Addressing socioeconomic determinants of smoking and integrating social needs screening and referrals into smoking cessation programs may be a promising approach for increasing cessation | - Tailoring:; – Intervened on socioeconomic challenges faced by people who smoked and had lower incomes; – Among participants who began the intervention, money management coaching was the most popular financial component of the intervention and the most feasible to integrate with the cessation coaching process; - Limitations:; – Abstinence was not biochemically verified; – Study occurred in a high-cost city with robust social services, and there was a considerable drop-off from screening to eligibility and completion, thus limiting generalizability; – Could not identify impacts of individual intervention components

Notes: CBT = cognitive behavioral therapy; CI = confidence interval; CO = carbon monoxide; ED = emergency department; FDA = U.S. Food and Drug Administration; MBAT = mindfulness-based addiction treatment; mg = milligram; mL = milliliter; ng = nanogram; NRT = nicotine replacement therapy; OR = odds ratio; ppm = parts per million; RCT = randomized controlled trial; VA = U.S. Department of Veterans Affairs.

Finally, Dahne and colleagues (2020b) performed a secondary analysis of an RCT that compared providing NRT samples (2-week supplies of nicotine patches and lozenges) with standard care among adults who smoked from 22 primary care clinics in South Carolina. The provision of NRT samples was associated with 7-day point-prevalence abstinence at 6 months post-intervention among participants with lower incomes (<$50,000 per year) (OR = 1.97; 95% CI, 1.13–3.42) but not among those with higher incomes (>$50,000 per year) (OR = 0.87; 95% CI, 0.39–1.94). Similar results were observed for education: the provision of NRT samples increased cessation among those with a high school diploma or less (OR = 2.23; 95% CI, 1.30–3.82) but not among those with higher educational attainment (OR = 0.89; 95% CI, 1.23–3.50).

Two of the six studies identified in the literature delivered out-of-clinic interventions; one study was among lower income pregnant women (Alaniz et al. 2019) and the other was among U.S. veterans and examined whether intervention effects differed by SES (Danan et al. 2018). Alaniz and colleagues (2019) tested whether adding one prenatal and three postpartum in-home counseling visits, three postpartum counseling phone calls, and up to $140.00 in gift cards to the First Breath cessation program was associated with greater biochemically confirmed smoking abstinence at 6 months postpartum compared with the original First Breath program (counseling in at least two prenatal visits and one postpartum visit, linkage to the Wisconsin quitline and texting program, one 6-month postpartum evaluation visit, and $40.00 in gift cards). Abstinence rates were 15.5% for women who received the postpartum intervention versus 7.4% for women in the control group (p = 0.07). The other RCT identified U.S. veterans from Veterans Administration electronic medical records and compared an active recruitment strategy (mailed materials followed by telephone outreach) that offered telephone smoking cessation counseling or referral to in-person counseling with usual care (Danan et al. 2018). The authors observed no statistically significant interaction between treatment arm and education (p = 0.07) or income (p = 0.74) for self-reported 6-month abstinence at 1-year follow-up. Participants at each education and income level had higher observed abstinence rates among those who were actively recruited to cessation treatment than among those in usual care.

#### Incentives

Interventions providing incentives (money, gift cards, and other tangible goods) are another approach that can engage lower SES people who smoke (USDHHS 2020). Evidence from a 2019 Cochrane review by Notley and colleagues (2019) estimated that a pooled RR from 31 RCTs for quitting with incentives at longest follow-up (6 months or more) compared with controls was 1.49 (95% CI, 1.28–1.73; adjusted N = 20,097). Excluding studies that took place in worksites (n = 10), the authors reported that 10 of the remaining 21 studies included in the meta-analysis included participants with diverse education and income levels and one additional study was among a lower SES population. Their review also estimated a pooled RR of 2.38 (95% CI, 1.54–3.69; N = 2,273) for cessation for pregnant women at longest follow (up to 24 weeks postpartum) from nine studies comparing incentives with controls. Among these nine studies, five studies were among lower SES women and one study comprised of women of diverse SES. Another meta-analysis of 22 RCTs among pregnant women concluded that when comparing treatment types, effects of contingency management interventions (i.e., providing financial incentives contingent upon biochemically verified smoking abstinence) for increasing smoking cessation were significantly greater than those of psychotherapeutic interventions (Wilson et al. 2018).

Three additional review articles examining incentives have been published since the 2019 Cochrane review (Getty et al. 2019; Breen et al. 2020; Hartmann-Boyce et al. 2021). One of these reviews, a 2021 Cochrane review of behavioral interventions for smoking cessation, concluded that there was high certainty evidence that guaranteed financial incentives increased smoking cessation at 6 months or longer compared with controls (OR = 1.46; 95% CI, 1.15–1.85; 19 studies, n = 8,877) (Hartmann-Boyce et al. 2021). A second review of 26 studies examined whether higher incentive amounts produced larger quit rates and found no correlation between the amount of the incentive and quit rates (Breen et al. 2020). Finally, a meta-analysis of seven RCTs concluded that interventions using contingency management delivered via mobile telephone performed significantly better than control conditions in increasing smoking cessation among adults with substance use disorders who were not in treatment (Getty et al. 2019).

The current literature review identified five studies examining the effect of incentives on cessation that were published since the 2019 Cochrane review of incentives for smoking cessation (Notley et al. 2019) and Kock and colleagues’ (2019) meta-analysis; these five studies are summarized in Table 7.9. Witman and colleagues (2018) performed a secondary analysis of data from the Medicaid Incentives for Prevention of Chronic Disease grant program and Medicaid claims and encounter data from five states (California, Connecticut, New York, Wisconsin, and New Hampshire). The authors observed that the receipt of incentives was positively associated with self-reported quit attempts, self-reported quits, or passing cotinine tests of smoking cessation in most programs, although the results were statistically significant in only a subset. The authors concluded that financial incentives are a promising policy lever to motivate behavioral change in those enrolled in Medicaid, but more evidence is needed regarding optimal incentive size, effectiveness of process- versus outcome-based incentives (i.e., participation in treatment versus cessation outcomes), targeting of incentives to populations of interest, and long-run cost-effectiveness (Witman et al. 2018).

Anderson and colleagues (2018) conducted an RCT of adult Medicaid beneficiaries enrolled in the California Smokers’ Helpline in which participants were randomized to one of three groups: usual care, nicotine patches, and nicotine patches plus a financial incentive of up to $60 for completing quitline counseling calls. A larger percentage of participants who received nicotine patches and incentives achieved 6-month prolonged abstinence (13.2%) compared with participants in usual care (9.0%; p = 0.001). However, no differences in most cessation outcomes were observed between participants who received the nicotine patches and participants who received usual care. The authors concluded that modest, noncontingent financial incentives increased smoking cessation among Medicaid enrollees and that such incentives could feasibly be integrated into existing quitline services.

Another RCT of adults enrolled in Medicaid from 12 health clinics in Connecticut randomly assigned participants to usual care or one of three incentive arms (financial incentives for 2 months; financial incentives plus a deposit contract with the incentive earnings after the 2 months, in which earnings would be lost if cessation is not achieved; and financial incentives plus a precommitment of incentives earnings into a deposit contract after the 2 months) (Anderson et al. 2021). No statistically significant differences in quit rates were observed when comparing each of the treatment groups with usual care at 2- or 6-months post-enrollment.

A recent RCT examined financial incentives for smoking cessation in a lower income population of 182 hospitalized adults (Ladapo et al. 2020). Participants were randomized to either enhanced usual care, which included hospital-directed cessation care and a quitline referral, or enhanced usual care plus up to $550 for participation in quitline counseling, community-based cessation programs, use of pharmacotherapy, and biochemically confirmed smoking cessation at 2 months and 6 months. The 6-month rate of biochemically confirmed smoking cessation was 19.6% in the incentive group and 8.9% in the enhanced usual care group (OR = 2.56; 95% CI, 0.84–7.83). The authors concluded that further research on the effectiveness of financial incentives that are sufficiently large to overcome barriers to the use of evidence-based therapy, is needed, as the total mean payment in their study was only $84 in the incentive group.

An RCT of pregnant and newly postpartum women with lower SES in Vermont also found that, compared with women who received best practice cessation interventions, those who received best practices plus financial incentives (vouchers redeemable for retail items, which were contingent on biochemically verified abstinence at clinic visits, of up to $865–$1,730 antepartum and $360–$720 postpartum, depending on initial amount of cigarette smoking) were more likely to quit during pregnancy and through 12 weeks postpartum but not at 24 or 48 weeks postpartum (Higgins et al. 2022b).

#### Summary

In summary, research indicates that behavioral interventions such as in-person and telephone counseling, digital support, and brief clinical interventions are effective for smoking cessation among lower SES population groups as summarized in the largest meta-analysis conducted to date (Kock et al. 2019) and the Clinical Practice Guideline (Fiore et al. 2008). However, it is important to note that two smaller review articles had mixed findings for the effectiveness of behavioral interventions or a combination of behavioral and pharmacologic interventions on smoking cessation among people with lower SES (Bryant et al. 2011; Hill et al. 2014). Kock and colleagues (2019) also concluded that tailored programs were not more effective for cessation among lower SES people compared with nontailored programs.

Seven additional RCTs identified in this literature review also reported mostly positive results for cessation interventions, although two studies observed no intervention effect (Bock et al. 2014; Alaniz et al. 2019). Among the five studies that found positive treatment effects, findings varied by whether the effect size varied by SES and by length of follow-up. Specifically, Danan and colleagues (2018) found no difference by SES, but Dahne and colleagues (2020b) found a larger effect among those with lower SES. With respect to follow-up length, Bernstein and colleagues (2015) observed a positive effect at short-term, but not long-term, follow-up; Rogers and colleagues (2022a) observed a positive effect on cessation at 6 months; and Vidrine and colleagues (2016) found a positive treatment effect only for abstinence at 26 weeks among those who were still smoking 4 weeks post-quit date.

Table 7.9 Individual-level tobacco cessation treatment trials of incentives for smoking cessation among people of lower socioeconomic status who smoke

Study | Design, population, and location | Intervention | Smoking cessation-related finding(s) | Tailoring to the population and study limitations
Anderson et al. (2018) | - Three group RCT; - Adult Medicaid beneficiaries calling the California Smokers’ Helpline in 2012–2013 (n = 3,816); - Primary quit smoking outcomes measured:; – 6-month prolonged abstinence; - California | - Usual care: Quitline counseling, cessation medication (NRT, bupropion, or varenicline) via a doctor’s prescription, and proof of enrollment in counseling to access free quitting aids at the local pharmacy; - Nicotine patch: Same as usual care plus NRT sent by the quitline via express mail in 4-week supplies with unlimited refills as long as the person was engaged in counseling and quitting; - Nicotine patch and financial incentives: Usual care and nicotine patch plus a $20 gift card for completing a pre-quit counseling call and a second gift card based on the number of completed follow-up counseling calls ($10 per call, up to $40) | - In the intent-to-treat analysis, members in the group receiving the nicotine patch and financial incentives were more likely to achieve 6-month prolonged abstinence than those in the usual care group (13.2% vs. 9.0%; p = 0.0001) and those in the nicotine patch group (10.3%; p = 0.02); - Abstinence of more than 6 months did not differ between members in the nicotine patch group and those in the usual care group (p = 0.27) | - Tailoring:; – Removed a treatment barrier by mailing nicotine patches to participants, eliminating the need for a prescription and a trip to a pharmacy; - Limitations:; – The incentives tested were adjuncts to a telephone counseling program so the results do not address the value of incentives as standalone interventions; – Could not determine the effect of the incentives without the use of a nicotine patch; – Widespread promotion of incentives through the quitline in all participant groups reduced the study’s power to detect a difference in the incentive comparison; – Evaluation staff were not blinded to group assignments; – Outcomes were not biochemically verified
Witman et al. (2018) | - RCT; - Secondary analysis of data from the Medicaid Incentives for Prevention of Chronic Disease program; - Primary quit-smoking outcomes measured:; – Outcomes varied by state and included self-reported quit attempts, self-reported quits, and biochemically verified cessation (cotinine <80 ng/ml or a negative CO test after a baseline test); – Data from each state were analyzed separately; - Logit models adjusted for sex, age, race, ethnicity, education level, and program time; - Five states, California, Connecticut, New Hampshire, New York, and Wisconsin | - Each state designed and implemented its own program; - Each program included multiple incentive arms; - Of the 12 incentive groups, many had behavioral counseling and some had NRT | - Incentive recipients in all program arms, except Connecticut’s program, were more likely to exhibit behavioral changes (self-reported quit attempts, self-reported quits, and/or passing CO/cotinine test between baseline and final measurement) than participants in control groups; the difference in cessation outcomes between participants in the incentive and control groups were statistically significant in 5 of the 12 programs | - Tailoring:; – California: Incentives included free NRT and incentives to participate in quitline calls; – Connecticut: Incentives for receiving in-person or telephone counseling and/or passing tobacco-free cotinine tests; – New Hampshire: Incentives for obtaining an NRT prescription and passing cotinine tests; – New York: Incentives for counseling or for passing cotinine tests; – Wisconsin: Engaged both pregnant and nonpregnant women who smoked; - Limitations:; – The number of participants may have been too small to detect statistically significant differences in outcomes; – Self-reported quit attempts and smoking cessation are subject to bias because a beneficiary’s response may have been related to having received a financial incentive
Ladapo et al. (2020) | - RCT; - Lower income adults (n = 182) who were hospitalized in Veterans Affairs hospitals; - Primary quit smoking outcomes measured:; – Tobacco abstinence—defined as self-reported, 7-day point-prevalence and biochemical confirmation with salivary cotinine (<10 ng/ml)—6 months after hospital discharge; - Other outcome: 2-month follow-up abstinence (CO <6 ppm); - Manhattan, New York | - Enhanced usual care: Hospital-directed tobacco-use screening, counseling, education, and pharmacotherapy and referral to state quitline; - Enhanced usual care and financial incentives: Enhanced usual care plus up to $550 (secure prepaid debit card) for participating in counseling (community-based and quitline), using smoking cessation pharmacotherapy, and achieving biochemically confirmed smoking cessation at 2 and 6 months | - Intent-to-treat analysis.; - 6-month rate of smoking cessation, based on biochemical confirmation:; – 19.6% in the enhanced usual care and financial incentives group:; – 8.9% in the enhanced usual care group; – OR = 2.56; 95% CI, 0.84–7.83; p = 0.10; - Financial incentives increased self-reported smoking cessation and the rate of early NRT use; - Financial incentives did not significantly increase the rates of other activities linked to incentives, including quitline participation | - Tailoring:; – Study designed to improve health through smoking cessation and to improve economic well-being through substantial cash payments for achieving healthy goals; - Limitations:; – Although patients could earn up to $550 in incentive payments over a 6-month period, the mean payment in the financial incentive arm was modest ($84) and fewer than 1 in 10 patients earned at least $400; – Financial stress was unchanged among those earning higher incentives but increased among those earning lower or no incentives; – Low power to detect a significant effect of incentives on cessation; – Population was limited to veterans and was more than 90% male; – Patients in the Veterans Affairs hospitals experience high levels of mood disorders, which may decrease the likelihood of cessation
Anderson et al. (2021) | - RCT; - Adult Medicaid beneficiaries (n = 311) at 12 health clinics; - Primary quit smoking outcomes measured:; – Smoking cessation confirmed biochemically at 2, 6, and 12 months (CO <8 ppm as a screener and urine cotinine <20 ng/mL); - Participants without biochemical verification from a urine cotinine test were recorded as still smoking; - Connecticut | - Usual care: Encouraged participants to use the clinic’s usual care cessation support services, including group counseling and NRT, and the state’s quitline; - Treatment Arm 1: Usual care and opportunity to earn incentives for 2 months (total possible reward of $300 in gift cards); - Treatment Arm 2: Usual care and opportunity to earn incentives for 2 months and start a 4-month deposit contract (where participants forfeit money if a cessation target is not met) after incentives ended (total possible reward of $300 in gift cards); - Treatment Arm 3: Usual care and opportunity to earn incentives for 2 months and option to precommit incentive earnings into a 4-month deposit contract after incentives ended (total possible reward of $300 in gift cards); - All treatment arms were registered to a study-specific web-based portal that (a) provided goal monitoring, online contracts, connections to anyone to support participants’ cessation efforts, and a journal for participants to log entries about their cessation progress and (b) offered a tool for participants to sign up for usual care | - Differences in quit rates did not differ significantly between those receiving usual care and those in any of the treatment groups; - Controlling for age, sex, education level, and income level at 2 months:; – Treatment Arm 1: OR = 1.71; 95% CI, 0.53–5.51; p = 0.37; – Treatment Arm 2: OR = 3.24; 95% CI, 0.86–12.25; p = 0.08; – Treatment Arm 3: OR = 3.03; 95% CI, 0.85–10.79; p = 0.09; - Controlling for age, sex, education level, and income level at 6 months:; – Treatment Arm 1: OR = 0.89; 95% CI, 0.13–6.03; p = 0.90; – Treatment Arm 2: OR = 0.84; 95% CI, 0.06–11.07; p = 0.89; – Treatment Arm 3: OR = 4.08; 95% CI, 0.70–23.90; p = 0.12; - Analysis of any treatment versus usual care also yielded nonsignificant ORs; - Only three participants were measured as not smoking at 12 months, so ORs were not modeled; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – The relatively high uptake of commitment contracts in the precommitment arm (Treatment Arm 3) suggests creative deposit contracts are feasible additions to financial incentive programs | - Tailoring:; – Deposit contracts (forfeit own money if cessation target is not met) usually have low uptake, but this program tried to increase uptake by combining financial incentives for cessation with the opportunity to commit incentive earnings to a deposit contract; - Limitations:; – Financial incentives did not induce cessation during the initial 2-month period, so most precommitment contracts were not funded, thereby limiting the ability to evaluate the precommitment treatment arm (Treatment Arm 3); – Small numbers due to lower than planned enrollments yielded imprecise estimates; – Lack of internet access or literacy may have been a barrier to engagement with the web-based portal
Higgins et al. (2022b) | - RCT; - Pregnant and newly postpartum women, ≥18 years of age (n = 249); - Mostly lower socioeconomic status, and 76–80% had less than 12 years of education; - Primary quit smoking outcomes measured:; – 7-day point-prevalence abstinence antepartum and postpartum; - Burlington, Vermont | - Control: Best practices for smoking cessation, including referral to the Vermont quitline for perinatal-specific counseling—with the quitline offering up to $65 in incentives for completing calls—and brief counseling from research staff at all assessments; - Financial Incentives: Best practices for smoking cessation plus voucher-based financial incentives from quit data through 12-weeks postpartum; vouchers (maximum $1,225–$2,450) were redeemable for retail items and earned contingent on CO <6 ppm during the initial 5 days of cessation, then contingent on urine cotinine levels <80 ng/ml | - Intent-to-treat analysis; - Compared with only best practices, best practices and financial incentives increased abstinence in early pregnancy (aOR = 9.97; 95% CI, 3.32–29.93) and late pregnancy (aOR = 2.46; 95% CI, 1.05–5.75) but not at 24-weeks (aOR = 1.31; 95% CI, 0.54–3.17) and 48-weeks postpartum (aOR = 1.33; 95% CI, 0.55–3.25); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Suggests a benefit of intervention beyond discontinuation of incentives | - Tailoring:; – No specific tailoring identified; - Limitations:; – Small sample size reduced statistical power to detect an effect; – Study population is from one state and may not be generalizable

Notes: aOR = adjusted odds ratio; CI = confidence interval; CO = carbon monoxide; mL = milliliter; ng = nanogram; NRT = nicotine replacement therapy; OR = odds ratio; ppm = parts per million; RCT = randomized controlled trial.

Regarding incentives, four meta-analyses consistently concluded that incentives increase cessation among lower SES population groups (Wilson et al. 2018; Getty et al. 2019; Notley et al. 2019; Hartmann-Boyce et al. 2021), although the one meta-analysis that sought to assess the optimal financial incentive amount for cessation could not determine the optimal amount (Breen et al. 2020). Five additional studies found mixed results for incentives, with two showing positive effects (Anderson et al. 2018; Witman et al. 2018), two showing no effect (Ladapo et al. 2020; Anderson et al. 2021), and one showing a short-term positive effect but no long-term effect (Higgins et al. 2022b). This evidence suggests that, when coupled with cessation treatments, incentives may increase successful cessation in this population group.

The most common approaches in designing cessation interventions for lower SES population groups to date include multicomponent interventions delivered in medical settings and incentive-based interventions. Further research is needed to identify the components of behavioral interventions that are most effective for lower SES population groups. Furthermore, as current tailoring strategies generally do not appear to be more effective at increasing cessation than nontailored strategies for lower SES population groups, additional research is needed to further the understanding of tailoring strategies that could be effective, including what types of interventions and the “dose” of tailoring that may be needed. In addition, future research studies could examine preferences for cessation medications among lower SES people who smoke, identify innovative strategies to increase medication use, and identify approaches to ensure equitable access to counseling and pharmacotherapy, particularly in lower resource settings.

### Black or African American People

Tobacco use is a major contributor to the three leading causes of death among African American people—heart disease, cancer, and stroke (USDHHS 1998; Heron 2013; Kochanek et al. 2016). Although African American or Black people usually smoke fewer cigarettes and start smoking cigarettes at an older age, they are more likely to die from smoking-related diseases than White people (USDHHS 1998, 2004; Heron 2013; Schoenborn et al. 2013; Kochanek et al. 2016). Among African American adults (≥18 years of age) who currently smoke cigarettes daily, 63.4% reported attempting to quit in the past year compared with 56.2% of Hispanic adults and 53.3% of White adults (USDHHS 2020). Despite a higher proportion of African American adults making quit attempts each year, they are less successful at quitting smoking than their White and Hispanic counterparts, possibly in part because of lower access to and/or utilization of cessation treatments, such as counseling and medication (USDHHS 2020), targeted tobacco industry marketing, elevated distress, and perceived racial discrimination (see Chapters 4 and 5). Three meta-analyses and an additional five trials (Table 7.10, meta-analyses not included) have examined the effectiveness of individual-level cessation intervention components among Black or African American people who smoke.

The Clinical Practice Guideline examined the effectiveness of cessation interventions for cigarette smoking among specific racial and ethnic groups and identified eight RCTs among African American adults (Fiore et al. 2008). The review found that medication (including bupropion sustained release and the nicotine patch in particular), counseling (including in-person motivational counseling, telephone counseling, and clinician advice), biomedical feedback, and tailored self-help manuals or materials have been shown in various RCTs to be effective in helping African American adults quit smoking.

Another 2008 meta-analysis of cessation interventions among African American adults was not limited to RCTs and comprised 20 studies (including six studies identified by the Clinical Practice Guideline [Fiore et al. 2008]) with 12,743 participants (Webb 2008b). Meta-analysis of cessation at the first follow-up assessment (follow-up times varied by study) in 12 studies found that cessation interventions were effective among African American adults (OR = 1.31; 95% CI, 1.02–1.69). Interventions tested in the included studies included medication (NRT, bupropion), counseling (individual, group, and telephone counseling), targeted or tailored print materials, community outreach, video and radio media, or some combination.

Webb (2008b) also observed that the effects of interventions with a culturally specific adaption and interventions without a culturally specific adaption on cessation varied over time. The authors examined smoking abstinence at first posttreatment assessment and found that studies testing a culturally specific smoking cessation intervention had significantly higher odds of cessation (OR = 1.47; 95% CI, 1.12–1.91) compared with control conditions; the odds of cessation for studies not testing a culturally specific intervention at first posttreatment assessment were not statistically significantly higher than control conditions (OR = 1.34; 95% CI, 0.99–1.82). However, at the first subsequent follow-up assessment, the cessation interventions that were not culturally specific had significantly higher odds of cessation (OR = 1.35; 95% CI, 1.02–1.78) compared to control conditions, whereas the effect for culturally specific interventions was not statistically significant compared to the control conditions. The author concluded that African American adults who smoke appear to respond to culturally specific cessation interventions during and at the end of treatment, which may be important for encouraging enrollment, reducing attrition, and completing treatment. However, the benefits of culturally tailored interventions may decline over time, and nontailored treatments have shown the greatest impact at follow-up (Webb 2008b).

Table 7.10 Individual-level tobacco cessation treatment trials among Black or African American people who smoke

Study | Design, population, and recruitment location | Intervention | Smoking cessation-related finding(s) | Tailoring to the population and study limitations
Nollen et al. (2007) | - RCT; - African American adults (n = 500); - Participants wanted to quit smoking in next 30 days or next 6 months and smoked >10 cigarettes per day. They also had to have access to a telephone and a VCR; - Primary quit-smoking outcomes measured: Biochemically verified 7-day smoking status at 6 months; - Secondary cessation outcomes included biochemically verified 7-day smoking status at 4 weeks, change in the number of cigarettes smoked, and readiness to quit at 4 weeks and 6 months; - Recruited through a large urban hospital in Atlanta, Georgia, where half of facility visits are provided to persons who are medically indigent | - Condition 1: Smoking cessation videotape (The Harlem Health Connections’ Kick-It) and guide (Pathways to Freedom: Winning the Fight Against Tobacco), both tailored for African American people; - Condition 2: Standard (untailored) videotape (American Medical Association’s How to Quit) and guide (ALA’s Freedom from Smoking); - Both conditions received 8 weeks of NRT (patches), a follow-up visit at Week 4, and reminder phone calls at Weeks 1 and 3 | - Intent-to-treat analysis; - No differences in 7-day abstinence at 6 months: Condition 2 (14.4%) compared with Condition 1 (18.0%) (p = 0.27); - No differences in 7-day abstinence at 4 weeks, change in the number of cigarettes smoked, or readiness to quit at 4 weeks and 6 months; - In Condition 2, participants with a low (vs. high) Afrocentric identity were significantly more likely to be abstinent at 6 months (21% vs. 8%, p = 0.02); - In Condition 1, no significant differences by Afrocentric identity were observed for abstinence at 6 months; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – The depth of tailoring may have been inadequate; – Nontailored materials were less effective for those with a high Afrocentric identity, suggesting there may be limited benefit from nontailored approaches among individuals strongly connected to their racial or ethnic identity; – It may be important to match interventions to participants’ racial or ethnic identity, not only their membership in a particular group.; – Participants were more likely to use the tailored guide, suggesting tailoring was effective for increasing attention and use. However, they did not report the deep structures as personally salient, suggesting heterogeneity among African American people | - Tailoring:; – Tailored materials were developed with input from African American people; – The Harlem Health Connections’ Kick-IT video addressed multiple deep structures, including storytelling, drivers of smoking (e.g., stress, racism, poverty), references to slavery, and additional cultural values; – Pathways to Freedom included depiction of African American people and addressed population-specific issues, including industry targeting; historical, cultural, and socioeconomic influences; and specific barriers and cultural strengths for cessation; - Limitations:; – Assessment of differences in the conditions may have been hampered by the success of the nicotine patch; – Participants were motivated to quit and had access to a telephone and VCR. It is unclear if findings would apply to people not motivated to make a quit attempt or without access to technologies; – The study was not blinded to investigators
Webb (2008a, 2009) | - RCT; - African American adults, 18–65 years of age, (n = 261) who smoked ≥5 cigarettes per day; - Participants who smoked were recruited through newspapers, urban radio stations, community-based organizations, hospitals, health clinics, and a focus group; - Primary quit-smoking outcomes were measured at 3 months after mailing of a smoking cessation booklet:; – Readiness to quit smoking; – 24-hour quit attempt; – 24-hour and 7-day point-prevalence abstinence | - Condition 1: Self-help smoking cessation booklet, Pathways to Freedom, tailored for African American people (culturally specific booklet); - Condition 2: Standard self-help smoking cessation booklet for people who smoked in the general population (i.e., not culturally specific) | - Intent-to-treat analysis; - Greater readiness to quit scores and 24-hour quit attempts were found in Condition 2 (45%) compared with Condition 1 (31%) (p = 0.05); - Abstinence rates did not differ between conditions:; – 24-hour abstinence: Condition 2 (14.7%) compared with Condition 1 (13.7%); – 7-day point prevalence abstinence: Condition 2 (9.3%) compared with Condition 1 (10.7%) (p = 0.05); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Culturally specific material was more encouraging, informative, helpful, and able to capture attention; the standard booklet was seen as more credible or trustworthy; – Acculturation modified the relationship between treatment condition and readiness to quit and 24-hour point-prevalence abstinence; – Readiness to quit increased with increasing levels of traditional African American values in the culturally specific condition and decreased in the standard condition; however, the opposite relationship was found for 24-hour abstinence, wherein abstinence decreased with increasing levels of traditional values in the culturally specific condition but increased in the standard condition | - Tailoring:; – Pathways to Freedom included known African American values, communication patterns, familial roles, history, religion and spirituality, statistics, and targeting of advertising for menthol cigarettes to mobilize the community to work against the tobacco industry—stating that materials were written for African American people to include pictures of only African American people, testimonials; stereotypical African American names, and established Pan-African colors; - Limitations:; – No biochemical verification of self-reported smoking status
Froelicher et al. (2010) | - RCT, community-based participatory research; - African American adults (n = 60), ≥21 years of age, who used tobacco in the past month, were willing to quit, and could read and speak English; - Primary cessation outcomes measured: Biochemically or family or friend-verified 7-day point prevalence smoking status at 6 and 12 months; - Recruited from a predominantly African American lower income neighborhood in San Francisco, California | - Condition 1: Condition 2 intervention plus: (a) tailoring of the CBT to include components related to social justice and industry targeting; (b) an unmodified Pathways to Freedom guide; - Condition 2 (control): 1-hour pre-class orientation session followed by a 5-week group CBT smoking cessation intervention, including a modified Pathways to Freedom guide where sections on social justice messages were removed; - For both conditions, participants reporting severe withdrawal or smoking >25 cigarettes per day were offered free NRT (patches or lozenges); all participants were referred to the state quitline | - Intent-to-treat analysis; - No significant difference in 7-day abstinence at 6 months between Condition 1 and 2 (13.6% vs 11.5%; p >0.05); - No significant difference in 7-day abstinence at 12 months between Condition 1 and 2 (15.8% vs 5.3%; p >0.05); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Knowledge about the harms of smoking and belief in the benefits of quitting were substantial, yet smoking histories indicated very low levels of self-efficacy for resisting the urge to smoke in high-risk situations. This finding may indicate that people who smoke are vulnerable to denial of risk and that information alone is not sufficient to fully inform people who smoke; – The level of addiction of people who smoke in socioeconomically marginalized circumstances may require more aggressive cessation interventions | - Tailoring:; – Tailored intervention was co-developed with community partners; – Included key messages about tobacco industry targeting, community empowerment, and social justice; – Internal tobacco industry documents were shown to participants and revealed the industry’s targeting and psychographic studies of African American people.; – Included discussion of how African American people are disproportionately harmed by tobacco and provided exposure to community members who had successfully quit smoking.; - Limitations:; – Study underpowered due to recruitment difficulties; – Recruitment included a brief social justice “teaser,” which could have made it difficult to find a difference between the groups; – Standard intervention included a modified Pathways to Freedom guide, which also included cultural tailoring
Webb et al. (2010a) | - RCT; - African American adults who smoked (n = 154); 36% of whom had a household income <$10,000 per year; - Primary quit-smoking outcomes measured:; – Biochemically verified smoking status at 3- and 6-month follow-up; - Recruited from medium-size city in the northeastern United States | - Condition 1: Group CBT; - Condition 2: GHE; - Both conditions received six CBT sessions and 8 weeks of NRT (patches) | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking):; – CO-verified 7-day point-prevalence abstinence was significantly greater in the CBT condition than it was in the GHE condition:; ○ At end of counseling, 50.7% in CBT versus 27.3% in GHE (OR = 2.74; 95% CI, 1.40–5.36; p = 0.003); ○ At 3-month follow-up, 33.8% in CBT versus 19.5% in GHE (OR = 2.11; 95% CI, 1.01–4.40; p = 0.047); ○ At 6-month follow-up, 31.2% in CBT versus 14.3% in GHE (OR = 2.72; 95% CI, 1.22–6.05; p = 0.014); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Group smoking cessation interventions can help motivated African American people to quit smoking | - Tailoring:; – Proactive recruitment strategy at community events frequented by African American people; no cultural tailoring of intervention materials; - Limitations:; – Sample was motivated to quit smoking; – Intervention effects may not generalize to unmotivated African American people who smoke; – No testing of culturally specific components
Nollen et al. (2011) | - Pilot RCT; - Black adults, ≥18 years of age, who smoked >10 cigarettes per day and had an intention to quit (n = 72); - Most participants were female (62.5%), had low income (58.2% with family income <$1,800 per month), and smoked menthol cigarettes (81.7%); - Primary quit smoking outcomes measured:; – Salivary cotinine-verified 7-day abstinence at Month 3 (<20 ng/mL); – Carbon monoxide-verified abstinence at Months 1 and 2 (<10 ppm); – Reduction in the number of self-reported cigarettes smoked per day from baseline to Month 3; - Community-based clinic in Kansas | - Condition 1: varenicline plus standard care; - Condition 2: varenicline plus five adherence counseling sessions on Days 8, 12, 20, 30, and 60; - Both conditions received standard counseling during randomization to develop a quit plan on Day 8 | - No significant difference in cotinine-verified abstinence at Month 3 between Conditions 2 and 1 (22.2% vs 25.0%, p = 0.78); - No significant difference in reduction in the number of cigarettes smoked per day between Conditions 2 and 1 (5.7% vs 7.4%, p = 0.31); - Overall association between medication adherence in both groups and smoking abstinence: mean adherence rates among participants who quit at Months 1 and 3 were 95.5% and 95.8% vs 85.6% and 80.8% among those who did not quit (p <0.05); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Quit rates in this sample of Black adults treated with varenicline were lower than those reported in clinical trials for White adults; – Although medication adherence rates were relatively high, adherence-based counseling did not affect overall quit rates at Month 3 | - Tailoring:; – All participants received a culturally tailored guide that addressed smoking cessation and abstinence and contained information about varenicline; - Limitations:; – Pilot study with small sample size; – Possible cointervention effect because of method of tracking medication adherence (use of pill boxes and pill counts); – Findings may not be generalizable to other populations of Black adults who smoke
Sanderson Cox et al. (2012) | - Randomized, double-blind, placebo-controlled trial; - African American adults who smoked lightly (i.e., 1–10 cigarettes per day) (n = 540); - Primary quit-smoking outcomes measured:; – Biochemically verified smoking status at 7 weeks (end of medication treatment) and 26 weeks; - Kansas City, Missouri | - Condition 1: 300 mg bupropion for 7 weeks (150 mg once daily for 3 days and then 150 mg twice daily); - Condition 2: Placebo for 7 weeks; - Both conditions had six scheduled health education counseling sessions that were delivered in person and by phone using the Kick It at Swope: Stop Smoking Guide | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking):; – Cotinine-verified 7-week point-prevalence abstinence at end of medication was significantly higher in the bupropion condition (23.7%) than it was in the placebo condition (9.6%) (OR = 2.92; 95% CI, 1.78–4.77; p <0.001); – No statistically significant difference occurred in 26-week point-prevalence abstinence for bupropion (13.3%) versus placebo (10.0%) (OR = 1.39; 95% CI, 0.82–2.35; p = 0.23); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Bupropion was effective in promoting smoking cessation among African American people who smoked lightly in the short term (7 weeks) and while taking medication, but bupropion showed no effect on long-term (26 weeks) abstinence | - Tailoring:; – Kick It at Swope: Stop Smoking Guide was culturally tailored for African American people who smoked lightly; - Limitations:; – Generalizability of findings to other people who smoke may be limited due to study inclusion criteria; – Lack of assessment between follow-up points limited the ability to characterize the process of relapse among people who smoked and initially took bupropion and achieved initial abstinence
Webb Hooper et al. (2014) | - RCT; - African American adults, 18–65 years of age, who smoked ≥5 cigarettes per day and had access to a DVD player (n = 140); - Participants were recruited through community flyers and word of mouth; - Primary quit-smoking outcomes measured:; – Readiness to quit at post-DVD viewing and 1-month follow-up; - Secondary outcomes at 1-month follow-up were 24-hour quit attempts or quitting smoking completely (yes or no); - South Florida | - Condition 1: Pathways to Freedom 60-minute, culturally tailored smoking cessation DVD; - Condition 2: 60-minute, standard smoking cessation DVD | - Participants in Condition 1 had greater readiness to quit smoking at 1-month follow-up than did participants in Condition 2 (p = 0.02); - 24-hour quit attempts and complete cessation during the previous 4 weeks varied by condition; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Compared with participants in Condition 2, participants in Condition 1 preferred the content of the culturally specific intervention—finding it more appealing and perceiving it to be more credible—and were more likely to share or recommend the DVD and recalled its content at follow-up; – The culturally specific, quit smoking video was identified as useful in increasing readiness to quit but not abstinence; – The DVD format is no longer widely used; instead, digital content can be easily streamed via the Internet | - Tailoring:; – Pathways to Freedom DVD was culturally tailored for African American people who smoked (see Webb 2009); - Limitations:; – Sample consisted mostly of people who smoked and had lower incomes, so findings may not be applicable to those with higher incomes; – People who smoked in the sample were not necessarily interested in smoking cessation, so the impact is unknown among people who are seeking help to quit smoking; – The sample from South Florida might not generalize to African American adults in other areas of the United States; – Study was not powered to detect smoking cessation; – Findings were based on self-reports
Cherrington et al. (2015) | - RCT; - Lower income African American adults, ≥19 years of age, who smoked and were in an inpatient ward with chronic illnesses (n = 300), 79% of whom reported that their income was not adequate to meet their basic needs; - Primary quit smoking outcomes measured:; – 7-day point-prevalence smoking status at 2 weeks; – Biochemically verified, continuous abstinence at 6 months; - Urban safety-net hospital in southern United States | - Condition 1 (intervention): Brief cessation counseling plus culturally tailored smoking cessation DVD; - Condition 2 (control): Brief cessation counseling plus nontailored DVD with a non-tobacco-related health message | - Intent-to-treat analysis; - Abstinence did not differ significantly between conditions at 2 weeks and at 6 months:; – 7-day point-prevalence abstinence at 2-week follow-up was 43.3% in the intervention group and 36.7% in the control group (p = 0.24); – Biochemically verified abstinence at 6 months was 15.3% in the intervention group and 11.3% in the control group (p = 0.16); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Narrative communication via culturally tailored storytelling to promote smoking cessation among African American people is insufficient as a standalone intervention | - Tailoring:; – Narrative communication via storytelling-based DVD developed for lower income, low-literacy African American people who smoked and had chronic illnesses; - Limitations:; – Findings and results are limited to African American people who smoke and are hospitalized in the southern United States and might not generalize to non-hospitalized African American people who smoke
Webb Hooper et al. (2017a) | - RCT; - Lower income African American adults, 18–65 years of age, who smoked (n = 342), 60.8% of whom reported an annual household income ≤$10,000; - Primary quit-smoking outcomes measured:; – Biochemically verified 7-day point-prevalence abstinence at the end of therapy and at 3-, 6- and 12-month follow-up; – Longitudinal intervention effect over the 12-month follow-up period was assessed by logistic regression analyses of condition on biochemically verified smoking outcomes; - South Florida | - Condition 1: Culturally tailored CBT group (8 sessions); - Condition 2: Standard CBT group (8 sessions); - Both conditions received 8 weeks of NRT (patches) | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - 7-day point-prevalence abstinence:; – Significant overall longitudinal effect (OR = 2.0; 95% CI, 1.11–3.58; p = 0.02); – End of therapy: 62.3% for the culturally tailored CBT group versus 51.5% for the standard CBT group (OR = 1.56; 95% CI, 1.00–2.42; p = 0.050); – 3-month follow-up: 36.4% for the culturally tailored CBT group versus 22.9% for the standard CBT group (OR = 1.92; 95% CI, 1.19–3.10; p = 0.007); – 6-month follow-up: 26.2% for the culturally tailored CBT group versus 22.0% for the standard CBT group (OR = 1.26; 95% CI, 0.76–2.08; p = 0.37); – 12-month follow-up: 23.2% for the culturally tailored CBT group versus 20.0% for standard CBT group (OR = 1.21; 95% CI, 0.71–2.04; p = 0.49); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – The effects of this culturally tailored behavioral intervention for smoking cessation appear to be short term. This may suggest that extended treatment is warranted. | - Tailoring:; – Surface- and deep-level structure elements relevant to African American culture—including matching race of clinicians to participants and addressing such topics as race and smoking, history of research distrust, concerns about NRT, meaning of being an African American, tobacco and African American people, menthol, spirituality and religion in the African American community, stressors unique to African American people, discrimination and racism, comorbid addiction, little cigars and blunt use, traditional African American values, and the buddy system—were added to evidence-based CBT techniques; - Limitations:; – Findings and results are limited to African American people who smoke in South Florida and might not generalize to African American adults in other areas of the United States
Chen et al. (2020) | - RCT; - n = 822; separate analyses for 270 African American adults who smoked, 306 adults of non-European ancestry who smoked (including the 270 African American adults in the analysis above), and 516 adults of European ancestry adults who smoked, ≥21 years of age; - Primary quit-smoking outcomes measured:; – Biochemically verified (CO <8 ppm) 7-day point-prevalence at the end of treatment (Week 12); - Secondary endpoints:; – 7-day point-prevalence abstinence with CO verification at 6 months; – 7-day point-prevalence abstinence at 1 year by self-report; - St. Louis, Missouri | - Participants were randomly assigned by CHRNA5rs16969968 genotypes to one of three treatments for 12 weeks:; – Varenicline tartrate; – cNRT; – Placebo varenicline tartrate or placebo nicotine patches and lozenges; - All treatment conditions received cessation counseling | - Among non-European ancestry group, both cNRT and varenicline were effective at the end of treatment:; – cNRT (17.8%) versus placebo (6.4%) abstinence; p = 0.019; – Varenicline (19.0%) versus placebo (6.4%); p = 0.021; - Among the non-European ancestry group, cNRT and varenicline were not effective at 6 months:; – cNRT (7.5%) versus placebo (10.6%) abstinence; p = 0.44; – Varenicline (17.1%) versus placebo (10.6%); p = 0.19; – Varenicline was effective at 6-months for the entire population, and cNRT was not effective; - The genotype-by-treatment interaction among African American people who smoked was significant for abstinence at the end of treatment but not at 6 and 12 months; - Compared with people in the placebo group, cNRT was more effective in people who smoked and had rs16969968 guanine-guanine genotypes, and varenicline was more effective in people who smoked and had guanine-adenine/adenine-adenine (or GA/AA) genotypes; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Genetic information may further enhance the effectiveness of cessation medications | - Tailoring:; – No specific tailoring identified; - Limitations:; – Small sample size of adults of non-European ancestry who smoked; – Variants were examined for one gene only; genome-wide polygenic scores have become an increasingly useful tool when predicting responses to medication
Nollen et al. (2020) | - RCT (two-arm, parallel-group individually randomized with allocation of 2:1 intervention to control); - Non-Hispanic Black adults who smoked but not daily (n = 278); - Primary quit-smoking outcomes measured:; – Biochemically verified, 30-day point-prevalence abstinence at the end of treatment (12 weeks) and at 26-week follow-up; – Self-reported days abstinent from all tobacco and reductions in the number of cigarettes smoked in the past 30 days; - Academic medical and federally qualified health centers in Kansas City, Missouri; Wichita, Kansas; and Nashville, Tennessee | - Condition 1: 12 weeks of in-person and telephone smoking cessation counseling plus NRT (either nicotine gum, patch, and/or lozenge); - Condition 2: 12 weeks of counseling | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking) revealed no significant differences in abstinence between conditions:; – Quit at Week 12: 11.4% for counseling plus NRT group and 8.6% for counseling only group (OR = 1.4, 95% CI, 0.6–3.2; p = 0.48); – Quit at Week 26: 7.0% for counseling plus NRT group and 6.5% for counseling only group (OR = 1.1, 95% CI, 0.4–3.0; p = 0.86); - Self-reported outcomes:; – The counseling plus NRT group reported a greater number of days abstinent (p <0.001) from all tobacco use and fewer numbers of cigarettes smoked (p = 0.002) in the past 30 days (measured at 12 and 26 weeks) than that reported by the counseling-only group; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – NRT delivered as an adjunct to smoking cessation behavioral counseling (a) did not improve abstinence relative to counseling alone for Non-Hispanic Black adults who smoked but not daily but (b) was associated with more days abstinent and a reduction in the number of cigarettes smoked in the past 30 days, with no evidence of compensatory behavior with non-cigarette tobacco products | - Tailoring:; – Intervention materials were tailored to nondaily smoking patterns and focused on managing smoking cues, triggers, and the positive reinforcement effects of smoking and addressing nicotine withdrawal and craving; - Limitations:; – Focused on only non-Hispanic Black adults who smoked cigarettes; therefore, findings may not generalize to people of other races and ethnicities who do not smoke daily or to Black people who smoke but not daily, who smoke infrequently, or smoke lightly; – Did not include Black adults who used alternative tobacco products (e.g., cigarillos or little cigars); – Did not provide placebo NRT; – Renumeration was provided for visit completion, which may limit generalizability; – Rates of NRT use were low; – Study was underpowered to detect a smaller effect size
Nollen et al. (2021) | - Secondary analysis of a four-arm RCT; - Black (n = 1,065) and White (n = 3,044) adults, 18–74 years of age, who smoked ≥10 cigarettes per day and were U.S. participants in EAGLES; - Primary quit-smoking outcomes measured:; – Biochemically verified continuous abstinence from Week 9 to Week 24.; - RCT in clinical trial centers, academic centers, and outpatient clinics in 29 states | - Condition 1: Varenicline (1 mg twice daily) for 12 weeks; - Condition 2: Bupropion (150 mg twice daily) for 12 weeks; - Condition 3: NRT (21 mg per day) with taper for 12 weeks (active control); - Condition 4: Placebo for 12 weeks; - All participants visited clinics weekly during Weeks 1–6 then biweekly during Weeks 7–12; up to 10 minutes of smoking cessation counseling was provided at each visit; - Smoking cessation counseling was also provided during follow-up at Weeks 13, 16, 20, and 24 | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Secondary, post hoc analysis revealed significant differences in biochemically confirmed continuous abstinence from Week 9 to Week 26 among Black adults in the varenicline group compared with the placebo group: OR = 2.63; 95% CI, 1.26–5.48; - No significant differences were seen in the relative efficacy of varenicline versus. bupropion or NRT, bupropion and NRT versus placebo, and bupropion versus NRT; - All treatments had greater efficacy than placebo among White adults who smoked.; - Black adults who smoked were less likely than White adults who smoked to quit across all treatment groups and among those with and without a psychiatric diagnosis; these racial differences remained after controlling for age, number of cigarettes smoked per day, cigarette dependence, lifetime quit attempts, discontinuation of the study drug, changes in depression or anxiety, and treatment for adverse events | - Tailoring:; – Secondary analyses controlled for differences between Black and White participants; compared with White participants, Black participants were older, smoked fewer cigarettes, were more dependent on nicotine, had a lower percentage of lifetime quit attempts, had lower rates of discontinuing treatment, had more positive changes in depression during the study, had higher levels of anxiety, and were less likely to be treated for an adverse event; - Limitations:; – Did not control for socioeconomic variables that are related to racial differences in abstinence; – Did not assess menthol use, nicotine metabolism, and social and environmental contexts associated with racism, discrimination, and increased stress; – EAGLES was not designed or powered to examine racial differences in abstinence.; – Follow-up was limited to 24 weeks.; – Study contained only adults with moderate to heavy smoking, so results may not be generalizable to the general population of people who smoke
Webb Hooper et al. (2021) | - Two-arm pilot RCT; - African American adults (n = 119) who smoked; reported having low household income; smoked ≥1 cigarette per day or had CO of ≥5 ppm; had a mobile phone with a data plan; and were willing to set a quit date within the next 14 days; - Primary quit-smoking outcomes measured:; – Biochemically verified, 7-day point-prevalence abstinence at the 6-week follow-up (end of intervention); - Mid-sized Midwestern city | - Condition 1: Six-week Path2Quit mobile health intervention that included the delivery of text messages with links to video segments from Pathways to Freedom; starter pack (i.e., 2 weeks supply) of nicotine patch or nicotine gum; and a brief behavioral counseling session; - Condition 2: Six- to eight-week SmokefreeTXT, a fully automated text-based cessation intervention; starter pack (i.e., 2 weeks supply) of nicotine patch or nicotine gum; and a brief behavioral counseling session | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking) revealed significant differences in biochemically confirmed 7-day point prevalence at 6-week follow-up (end of intervention); - Quit outcomes: 48% for Path2Quit group and 26% for SmokefreeTXT group (age-adjusted OR = 3.55; 95% CI, 1.32–9.54) | - Tailoring:; – Path2Quit mobile health intervention incorporated culturally specific content from Pathways to Freedom, a 60-minute video that includes surface elements (e.g., race-matched host, experts, and families; music; colors; and images) and deep structure elements (e.g., content focused on menthol cigarettes and alternative tobacco products, the health and financial costs of smoking, tobacco cessation pharmacotherapy, psychosocial stressors, and culturally relevant coping strategies to manage smoking urges); - Limitations:; – The small sample size, single geographic location, and short-term follow-up may limit the generalizability of the findings to other population groups and settings
Sanderson Cox et al. (2022) | - RCT (individually randomized with allocation of 3:2 intervention to control; randomization was stratified by level of smoking and sex); - African American adults who smoked ≥1 cigarette per day for at least 25 of the past 30 days (n = 500); - Primary quit-smoking outcomes measured:; – Biochemically verified, 7-day point-prevalence abstinence at the end of treatment (12 weeks) and at 26-week follow-up.; – Week 12 abstinence was also evaluated for light smoking (1–10 cigarettes per day) and moderate to heavy smoking (>10 cigarettes per /day); - Kansas City, Missouri | - Condition 1: Six sessions of counseling and 12 weeks of varenicline; - Condition 2: Six sessions of counseling and 12 weeks of placebo.; - All participants received the Kick It at Swope: Stop Smoking Guide, a culturally tailored educational guide | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking) revealed significant differences in 7-day point prevalence:; – Quit at Week 12: 18.7% for counseling plus varenicline group and 7.0% for counseling plus placebo group (OR = 3.0; 95% CI, 1.7–5.6; p <0.001); – Light smoking at Week 12: 22.1% for counseling plus varenicline group and 8.5% for counseling plus placebo group (OR = 3.0; 95% CI, 1.4–6.7; p = 0.004); – Moderate to heavy smoking at Week 12: 15.1% for counseling plus varenicline group and 5.3% for counseling plus placebo group (OR = 3.1; 95% CI, 1.1–8.6; p = 0.02); – Quit at Week 26: 15.7% for counseling plus varenicline group and 6.5% for counseling plus placebo group (OR = 2.7; 95% CI, 1.4–5.1; p = 0.002) | - Tailoring:; – Counseling incorporated content from the Kick It at Swope: Stop Smoking Guide and reviewed the disproportional risks of smoking for African American people; - Limitations:; – The generalizability of findings may be limited due to (a) inclusion criteria, as participants were restricted to those who were interested in stopping smoking and to those without major psychiatric comorbidities, and (b) renumeration for visit completion; – Study lacked the power to assess differences among subsets of light and heavy smoking at Week 26

Notes: CBT = cognitive behavioral therapy; CI = confidence interval; cNRT = combination nicotine patches and nicotine lozenges; CO = carbon monoxide; DVD = digital video disk; EAGLES = Evaluating Adverse Events in a Global Smoking Cessation Study; GHE = general health education; mg = milligram; MI = motivational interviewing; NRT = nicotine replacement therapy; OR = odds ratio; ppm = parts per million; RCT = randomized controlled trial.

Finally, in a meta-analysis of 15 RCTs (of which 4 were included in Webb [2008b] and 11 were published after Webb [2008b]), Montgomery and colleagues (2017) examined psychosocial and pharmacologic treatments for tobacco use among African American adults. Across all studies, they found higher odds of smoking abstinence among African American adults in the treatment condition (OR = 1.41; 95% CI, 1.11–1.78) compared with those in the control condition. In addition, cessation treatments increased both short-term (<4 months; OR = 1.39; 95% CI, 1.05–1.85) and long-term (>4 months; OR = 1.52; 95% CI, 1.22–1.89) cessation at follow-up. The authors also found no significant differences in the rate of smoking abstinence between culturally tailored treatments and nonculturally tailored control conditions (OR = 1.09; 95% CI, 0.76–1.55).

RCTs published since the 2008 review and meta-analysis (n=14) (Fiore et al. 2008; Webb 2008b) included studies that tested behavioral counseling modalities with varying levels of cultural tailoring for African American or Black adults who smoke (Table 7.10). Although nine of these studies were included in the review by Montgomery and colleagues (2017), they are also discussed here to provide more detail. Among the 11 studies published after Webb (2008b) and included in the meta-analysis by Montgomery and colleagues (2017), a cessation medication study by Ahluwalia and colleagues (2006) was also included in a cessation medication meta-analysis by Robles and colleagues (2008), so it was not included in Table 7.10.

Two RCTs tested the efficacy of group CBT plus 8 weeks of nicotine patch therapy among African American adults. One trial tested the generalizability of nonculturally tailored treatment (Webb et al. 2010a); the other trial tested the incremental benefit of culturally tailored intervention components (Webb Hooper et al. 2017a). Webb and colleagues (2010a) compared the effects of six sessions of standard CBT with the effects of attention-matched group health education. The study found that 7-day point-prevalence abstinence was greater after standard CBT than it was after group education at three time points: at the end of treatment (50.7% vs. 27.3%), 3 months after treatment (33.8% vs. 19.5%), and 6 months after treatment (31.2% vs. 14.3%). A subsequent trial compared eight sessions of standard (nontailored) group CBT with an attention-matched culturally specific adaptation (Webb Hooper et al. 2017a). Longitudinal intent-to-treat analysis using all study endpoints (end of therapy and 3, 6, and 12 months) demonstrated increased cessation (7-day point-prevalence abstinence) for the culturally specific intervention compared with the standard intervention (OR = 2.0; 95% CI, 1.11–3.58). However, when intervention effects were tested at individual time points, significantly greater odds of 7-day point-prevalence abstinence were observed in the culturally specific condition only at the end of therapy (OR = 1.56; 95% CI, 1.00–2.42) and 3-month follow-up (OR = 1.92; 95% CI, 1.19–3.10).

Froelicher and colleagues (2010) also tested the incremental benefit of adding culturally tailored intervention components to a 5-week CBT intervention. No significant differences in 7-day abstinence were observed between the culturally specific intervention focused on the tobacco industry’s targeting of African American people and media messages compared to the control group intervention at 6 or 12 months. However, the control group intervention included a modified Pathways to Freedom guide, which may have decreased the differences between the interventions.

Low-intensity behavioral interventions are less effective for tobacco cessation but demonstrate promise for increasing the antecedents of behavior change (i.e., readiness to quit and quit attempts) and for broadening reach. Webb (2009) randomly assigned African American adults who smoke to receive a stand-alone, culturally specific cessation booklet (Pathways to Freedom) or a standard booklet (an adapted version of Pathways to Freedom that replaced culturally specific content with generic content) that was the same length and included the same content as the culturally specific cessation booklet. Although the culturally specific materials were rated as more encouraging, informative, helpful, and able to capture attention, the standard booklet was seen as more credible and trustworthy. In addition, those assigned to the standard booklet had higher readiness-to-quit scores and were more likely to make a quit attempt (45%) than those who received the culturally specific booklet (31%; p = 0.05). Both 24-hour and 7-day point-prevalence abstinence at 3 months did not vary between the conditions. The study concluded that few studies have examined participants’ expectations for culturally specific interventions, that African American adults may have mixed expectancies for culturally specific interventions, and that some may be concerned that interventions targeting African American people may be of low quality. The study also concluded that more research is needed to understand how culturally specific approaches operate, including how factors such as racial and ethnic identity or level of acculturation may act as moderators of the effects of such interventions.

Webb (2008a) examined whether level of acculturation moderated the efficacy of smoking cessation interventions among lower income African American adults. The study found that those who were less acculturated (i.e., held more traditional African American cultural values, beliefs, and practices) had higher ratings for the culturally specific intervention, but those who were more acculturated (i.e., fewer traditional beliefs and practices) preferred the standard materials. The effect of the cessation interventions on readiness to quit also varied by acculturation. Among adults with a more traditional African American cultural orientation, the culturally specific intervention was related to greater readiness-to-quit smoking, whereas readiness decreased among those in the standard condition. In contrast, the opposite relationship was found for 24-hour point-prevalence abstinence. Specifically, a more traditional African American cultural orientation was related to lower odds of 24-hour quitting among those who received the culturally specific intervention and greater odds in the standard condition. The study concluded that readiness to quit can be increased by matching the type of intervention with individual levels of acculturation but also noted that the elements of cultural specificity in the culturally tailored intervention may have evoked an emotional response (e.g., mentioning slavery), which may have reduced attention to the content and distracted from the advice on quitting, ultimately reducing abstinence outcomes.

In another study that assessed a culturally specific video-based intervention, Webb Hooper and colleagues (2014) randomized African American adults who smoke to receive a Pathways to Freedom smoking cessation DVD or a time-matched standard smoking cessation DVD (60 minutes). Participants in the culturally specific condition had greater readiness to quit at 1-month follow-up than those in the standard DVD cessation condition (p = 0.02). However, 24-hour quit attempts and complete cessation during the preceding 4 weeks did not vary by condition.

Nollen and colleagues (2007) assessed the effect of a culturally tailored intervention that included a video (The Harlem Health Connections’ Kick-It Video) and the Pathways to Freedom guide. No differences were observed in biochemically confirmed abstinence at 4 weeks or 6 months between the culturally tailored intervention and the nontailored cessation video and guide intervention. In addition, no differences were observed in the number of cigarettes smoked or in readiness to quit at 4 weeks and 6 months. Similar to Webb (2008a), Nollen and colleagues (2007) observed differences in cessation by level of Afrocentric identity; however, this was statistically significant only among those receiving the nontailored intervention. Among the participants receiving the nontailored intervention, those with a low Afrocentric identity were significantly more likely to be abstinent at 6 months than those with a high Afrocentric identity (Nollen et al. 2007).

In contrast, Webb Hooper and colleagues (2021) observed that African American adults randomized to a culturally specific mobile health intervention (Path2Quit), which translated Pathways to Freedom into a video-text format, were more likely to have biochemically confirmed abstinence at 6-week follow-up than those randomized to receive the NCI’s text message-based cessation support program SmokefreeTXT (both groups also received a brief behavioral counseling session plus 2 weeks of NRT).

Finally, Cherrington and colleagues (2015) found greater intentions to quit among lower income African American adults who smoked who were randomly assigned to brief cessation counseling plus a video of narrative stories related to cessation compared with those assigned to brief counseling plus a video unrelated to tobacco. However, no significant differences in cessation outcomes at 2 weeks or 6 months were detected.

In sum, this body of research has demonstrated that there is a subset of African American or Black adults who smoke who prefer culturally tailored cessation materials, and these materials may enhance intermediate markers of movement toward cessation, including readiness to quit and quit intentions. However, tailored interventions to date have generally not been associated with increased successful cessation in this population group. Further research to determine whether culturally specific cessation interventions can result in greater reach or effectiveness among African American or Black people is warranted.

A somewhat limited body of research has focused on pharmacotherapy interventions specifically in samples of African American or Black adults who smoke. Robles and colleagues (2008), in reviewing the efficacy of smoking cessation pharmacotherapies in non-White populations, identified six studies in Black adults who smoked, including three RCTs (one on the nicotine patch, one on bupropion sustained release, and one on nicotine gum) and three secondary analyses of these original trials, focusing on the outcomes among those who smoked mentholated cigarettes versus those who smoked nonmentholated cigarettes. Based on their review, the authors concluded that nicotine patches and bupropion sustained release increased smoking cessation compared with placebo; however, no effect was observed among the subset of Black adults who smoked less than 10 cigarettes per day who received 2-milligram (mg) nicotine gum. The authors also noted that Black patients in these trials who smoked within 30 minutes of awakening, smoked mentholated cigarettes, and had high salivary cotinine levels were less likely to quit than those who had a longer time to smoking upon awakening, smoked nonmentholated cigarettes, and had lower cotinine levels. Similarly, another meta-analysis by Montgomery and colleagues (2017) found higher odds of smoking abstinence among African American adults using cessation pharmacotherapy than those using placebo controls (OR 1.69; 95% CI, 1.15–2.49).

Six studies on the effects of cessation medications have been published since Robles and colleagues’ (2008) review. Sanderson Cox and colleagues (2012) conducted a double-blind RCT comparing 7 weeks of bupropion (300 mg) with placebo among African American adults who smoked 10 or fewer cigarettes per day and were provided up to six sessions of health education counseling. The study found that those who received bupropion had significantly greater biochemically verified point-prevalence abstinence at the end of the 7-week medication phase compared with those who received placebo (23.7% vs. 9.6%, respectively; OR = 2.92; 95% CI, 1.78–4.77) but not at 26 weeks (13.3% vs. 10.0%, respectively; OR = 1.39; 95% CI, 0.82–2.35). The authors suggested medication adherence may have played a role in these findings, noting that individuals in the bupropion group who remained quit at Week 26 demonstrated higher medication adherence early in treatment than those in the bupropion group who continued smoking at Week 26. In addition, the authors called for further studies on the benefit of pharmacotherapy for adults who smoke fewer than 10 cigarettes per day with particular attention to increasing long-term abstinence among African American adults who fit this definition.

A subsequent study by Nollen and colleagues (2020) assessed the effectiveness of NRT plus counseling versus counseling alone among Black adults who smoked cigarettes 4–27 of the last 30 days and smoked at this rate for at least 3 months. Abstinence at 12-week follow-up was 11.4% in the NRT (choice of patch, gum, and/or lozenge) plus counseling condition and 8.6% in the counseling-only condition (p = 0.48). At 26-week follow-up, abstinence was 7.0% in the NRT plus counseling condition and 6.5% in the counseling-only condition (p = 0.86).

Chen and colleagues (2020) examined whether a genetic variant in the cholinergic receptor nicotinic alpha 5 subunit (or CHRNA5) affected the response to cessation medication. In the non-European American ancestry group as termed in the study (n = 306, which included 270 African American adults), combined use of nicotine patches and nicotine lozenges (vs. placebo) was effective at the end of treatment (12 weeks) but not at 6 months; similar findings were observed for varenicline. Among African American adults, the genotype by treatment interaction was significant at the end of treatment but not at 6 months. The authors concluded that genetic information may be useful as a clinical decision aid for the selection of cessation medications. More studies are needed to assess the potential utility of this approach to treatment. Additionally, as described in Chapters 1 and 3, race is a social construct and is best understood as a form of stratification rather than a distinct group of genetic dispositions (National Human Genome Research Institute 2023); further, there is greater genetic variance within versus between racial and ethnic population groups (Jorde and Wooding 2004; Mersha and Beck 2020).

In a pilot study by Nollen and colleagues (2011) comparing the effectiveness of varenicline plus standard care versus varenicline plus five additional adherence counseling sessions in 72 Black adults who smoked more than 10 cigarettes per day, the authors found no statistically significant differences between groups. At month 3, cotinine-verified abstinence rates were 22.2% for the group that received additional adherence support versus 25.0% for those who received standard care (p = 0.78). While not different between groups, there was an overall association between medication adherence and smoking abstinence; adherence rates at months 1 and 3 were 95.5% and 95.8%, respectively, among participants who quit smoking compared with 85.6% and 80.8% among participants who did not quit (p ≤0.05).

A recent trial by Sanderson Cox and colleagues (2022) of varenicline among 500 African American adults who smoked daily observed that participants receiving varenicline were significantly more likely than those receiving placebo to be abstinent at both the end of treatment Week 12 (18.7% vs. 7.0%, respectively; OR= 3.0; 95% CI, 1.7–5.6) and at Week 26 (15.7% vs. 6.5%, respectively; OR= 2.7; 95% CI, 1.4–5.1).

A secondary post hoc analysis of the Evaluating Adverse Events in Global Smoke Cessation Study (or EAGLES) RCT by Nollen and colleagues (2021) also observed among Black adults who smoked 10 or more cigarettes per day that varenicline had greater efficacy for biochemically verified continuous abstinence from Weeks 9 to 24 than placebo (OR= 2.63; 95% CI, 1.26–5.48). This study observed no significant differences in abstinence among Black adults treated with bupropion or NRT compared with placebo.

Nollen and colleagues (2021) also observed that Black participants were less likely than White participants to quit across all treatment groups including the group receiving the placebo. These differences remained after controlling for age, smoking amount, cigarette dependence, lifetime quit attempts, drug discontinuation, change in depression, higher baseline anxiety, and treatment adverse events (Nollen et al. 2021). The authors noted that among Black adults without a psychiatric diagnosis, both bupropion and NRT had higher efficacy than placebo during active treatment (Weeks 9–12). The authors concluded that long-term pharmacotherapy (>12 weeks) may be important for increasing abstinence for these medications given that their effects diminished at the end of treatment. They further concluded that future studies should explore pharmacotherapy efficacy for cessation among Black adults who smoke and have psychiatric comorbidities as this group may be particularly challenging to treat.

#### Summary

In summary, RCTs focused on Black or African American adults who smoke have found that behavioral cessation interventions, including in-person, group, and telephone counseling, are effective in this population (Fiore et al. 2008; Robles et al. 2008; Webb 2008b, 2010a; Montgomery et al. 2017). RCTs of culturally specific interventions for Black or African American adults have demonstrated the appeal of culturally specific materials for some population groups and that these interventions are associated with increased levels of readiness to quit (Webb 2008a, 2009; Webb Hooper et al. 2014; Cherrington et al. 2015). However, the culturally specific cessation interventions developed to date have generally not been associated with improved cessation outcomes compared with nontailored interventions, particularly in long-term follow-up.

Studies of pharmacotherapies (NRT, bupropion, and varenicline) among Black or African American adults who smoke have generally demonstrated efficacy of these treatments, particularly for varenicline (Nollen et al. 2011, 2021; Sanderson Cox et al. 2022). However, some recent studies have found an association between pharmacotherapy and short-term, but not long-term, cessation in this population (Sanderson Cox et al. 2012; Chen et al. 2020; Nollen et al. 2021) and two studies demonstrated no increase in cessation with either nicotine gum or self-selected NRT (gum, patch, and/or lozenge) among African American adults with light or nondaily smoking (Nollen et al. 2020).

Among Black or African American people, additional research is needed on culturally specific smoking cessation interventions (particularly because some strategies have been associated with intermediate cessation outcomes but not long-term cessation at follow-up), the barriers to and facilitators of the use of FDA-approved cessation medications, cessation interventions for people with mental health conditions or other substance use disorders, cessation interventions for those with a low frequency of smoking (intermittent [also called nondaily] or light daily smoking), and interventions for those who use flavored, including mentholated, tobacco products.

### American Indian and Alaska Native People

Among all racial and ethnic groups, the prevalence of commercial tobacco use is highest among American Indian and Alaska Native people, but relatively few intervention trials have focused on this population. The Clinical Practice Guideline examined the effectiveness of cessation interventions for cigarette smoking among specific racial and ethnic groups and identified one RCT that found that screening for tobacco use, clinician advice, clinic staff reinforcement, and follow-up materials were effective in four urban Indian Health clinics (Fiore et al. 2008).

Published trials have tested a combination of behavioral counseling and pharmacotherapy. Table 7.11 includes findings from three RCTs focused on American Indian and Alaska Native adults published since the Clinical Practice Guideline (Fiore et al. 2008). In one, Smith and colleagues (2014) conducted a two-arm RCT that compared culturally tailored individual counseling plus 12 weeks of varenicline with nontailored individual counseling plus the same pharmacotherapy in a sample of adults who smoked who were primarily from the Menominee Indian Tribe of Wisconsin. Across conditions, the overall biochemically verified 7-day point-prevalence intent-to-treat abstinence rate was 20% at 6 months, with no statistically detectable differences found between conditions (p >0.05). This study was limited by its small sample size, high attrition in the culturally tailored group, and possible contamination of the intervention due to the fact that all participants received a t-shirt with the study logo, enabling them to identify each other and potentially share information about the interventions.

Choi and colleagues (2016a) conducted a multisite RCT that compared the incremental efficacy of All Nations Breath of Life (ANBL)—a CBPR-informed culturally tailored smoking cessation intervention—with the incremental efficacy of a nontailored care approach among rural or reservation-based American Indian adults. Both interventions were comprehensive and included intensive education and group sessions. All participants, regardless of assigned intervention arm, had the option of choosing any or no pharmacotherapy. Using intent-to-treat analyses, self-reported 7-day point-prevalence abstinence rates at 6 months were 20.1% for the ANBL intervention and 12.0% for the nontailored care approach (p = 0.029). However, the cotinine-verified abstinence rates between the ANBL and nontailored care approach were not statistically significant, potentially because of high attrition and lower-than-expected biochemical collection rates.

Table 7.11 Individual-level tobacco cessation treatment trials among American Indian and Alaska Native people who smoke

Study | Design, population, and location | Intervention | Smoking cessation-related finding(s) | Tailoring to the population and study limitations
Smith et al. (2014) | - RCT; - American Indian adults who smoked (n = 103), 80% of whom were from the Menominee Indian Tribe; - Primary quit smoking outcomes measured:; – Biochemically verified 7-day point-prevalence abstinence at 6 months; - Wisconsin | - Condition 1: Culturally tailored treatment intervention group developed through a multistep, community-engaged process; - Condition 2: Usual care group receiving the general cessation treatment approach used in clinical services at the tribal clinic; - Both conditions received four sessions of individual smoking cessation counseling and 12 weeks of varenicline | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking):; – 14.0% abstinence in the culturally tailored treatment group versus 22.6% abstinence in the usual care group at 6-month follow-up (OR = 0.56; 95% CI, = 0.20–1.55; p = 0.26); – 20% quit smoking across conditions; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Supports the feasibility of partnerships between tribal community healthcare providers and academic partners to address commercial tobacco use; – Study did not find clear evidence that cultural tailoring yields higher abstinence rates | - Tailoring:; – Multistep process that engaged the target population in the development of the intervention; approach was based on the Indigenist Stress-Coping model; - Limitations:; – Small sample, high and differential attrition, and possible intervention contamination; – Missing data were attributable to high attrition in the culturally tailored treatment group
Choi et al. (2016a) | - RCT; - American Indian and Alaska Native adults who smoked and lived on reservations or in rural areas (n = 463); - Primary quit smoking outcomes measured:; – Biochemically verified (salivary cotinine) 7-day point-prevalence abstinence at 12 weeks and 6 months; - U.S. Southern Plains and Northern Plains regions | - Condition 1: ANBL, a culturally tailored smoking cessation intervention that included:; – In-person group counseling (nine sessions over 6 months) led by a facilitator who was American Indian; – Individual telephone counseling (four calls); - Condition 2: Usual care that included:; – Individual counseling (nine sessions over 6 months) led by a facilitator who was not American Indian; – Individual telephone counseling (four calls); – Nontailored, health education-based curriculum; - Both groups offered NRT (gum, patch, or lozenge), varenicline, or bupropion and minimal incentives that were tailored in Condition 1 and nontailored in Condition 2 (DVDs, CD, snacks, water bottles, and other novelties) | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Self-reported 7-day point-prevalence abstinence rates were statistically different between conditions:; – At 12 weeks: 27.9% in ANBL versus 17.4% in usual care (OR = 1.87; 95% CI, 1.07–3.26; p = 0.028); – At 6 months: 20.1% in ANBL versus 12.0% in usual care (OR = 1.91; 95% CI, 1.07–3.42; p = 0.029); - Cotinine-verified 7-day point-prevalence abstinence rates were not statistically different between conditions:; – At 12 weeks: 11.2% in ANBL versus 8.8% in usual care (OR = 1.31; 95% CI, 0.64–2.73; p = 0.46); – At 6 months: 10.8% in ANBL versus 6.9% in usual care (OR = 1.65; 95% CI, 0.80–3.43; p = 0.18); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Findings support potential effectiveness of ANBL for smoking abstinence | - Tailoring:; – ANBL intervention was developed using principles of CBPR that involved the target community (e.g., a facilitator who was American Indian delivered tailored intervention components, and a facilitator who was not American Indian delivered the usual care intervention components); – High level of engagement and participation from American Indian adults who smoked and represented several different tribes from various regions; - Limitations:; – High attrition and lower than expected biochemical collection rates
Dignan et al. (2019) | - RCT; - American Indian adults who smoked and resided in three sites in South Dakota: Pine Ridge (Oglala Sioux Tribe) and Rosebud Reservations (Rosebud Sioux Tribe) and Rapid City (n = 254); - Primary quit smoking outcomes measured:; – Biochemically verified (CO < 10 ppm) at 18-month follow-up visit; - Northern Plains | - Multicomponent intervention that included combinations of minimal or intense levels of four interventions: NRT, pre-cessation counseling, post-cessation counseling, and mHealth text messages; - A community research representative conducted all intervention visits in person or by telephone; - Participants were randomized to one of 15 groups. | - Multivariate logistic regression was used to evaluate main effects and interactions on the primary outcome of smoking cessation using an intent-to-treat analysis:; – At the 18-month follow-up visit—and after adjusting for age, education level, and ethnicity—receiving NRT was associated with increased odds of having stopped smoking (p = 0.05); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Use of NRT, as assessed at the 18-month follow-up visit, increased the odds of quitting smoking; – Additional research is needed to improve understanding of factors that influence enrollment and retention in smoking cessation interventions by American Indian adults | - Tailoring:; – Program guided by Theory of Planned Behavior; – Model used to identify American Indian-specific variables that contribute to explaining smoking and challenges to smoking cessation; – Cultural modifications to survey items, mHealth text, and counseling; – Community advisory committees provided program guidance; – Usability testing to ensure cultural relevance; - Limitations:; – Some subjects were more motivated to participate in the study in order to obtain a free cell phone than to stop smoking, which may have limited the rates of smoking abstinence and caused uncertainty about when NRT was used or started among subjects; – High rate of attrition from enrollment (n = 254) to quit date visit (n = 108) raises concerns that selection bias may have influenced the study outcomes

Notes: ANBL = All Nations Breath of Life; CBPR = community-based participatory research; CD = compact disc; CI = confidence interval; CO = carbon monoxide; DVD = digital video disk; mHealth = mobile health; NRT = nicotine replacement therapy; OR = odds ratio; ppm = parts per million; RCT = randomized controlled trial.

Finally, Dignan and colleagues (2019) randomized American Indian adults who smoked and resided in three South Dakota sites to 1 of 15 groups that included combinations of minimal or intense levels of each of four interventions: NRT, pre-cessation counseling, post-cessation counseling, and text message-based support. In multivariate logistic regression models controlling for age, education, and ethnicity, receiving NRT was associated with increased odds of having stopped smoking (self-reported smoking on day of visit biochemically verified by carbon monoxide <10 parts per million [ppm]) at the 18-month follow-up visit (p = 0.05) among those who continued participation throughout the study. This study was limited by substantial participant attrition.

Recent and ongoing research includes a pilot test of two versions of the All Nations Snuff Out Smokeless program, which is based on the ANBL smoking cessation program (Hale et al. 2020; Daley et al. 2021c) and two ongoing RCTs, including a culturally tailored text message intervention for smoking cessation among American Indian and Alaska Native adults recruited through five state quitlines (Alaska, Minnesota, New Mexico, Oklahoma, and Wisconsin) (Orr et al. 2019) and the Healthy Pregnancies Project for Alaska Native pregnant women (Patten et al. 2019). Additional research that tests the efficacy of commercial tobacco cessation interventions among American Indian and Alaska Native people is warranted and should address expectancies about the smoking cessation process and desirable program components identified using community-engaged principles (Fu et al. 2014a; Hendricks et al. 2014).

### Asian American People

As is the case with all racial groups in the United States, Asian American people are a heterogenous population group with heritage from many countries and multiple languages spoken. The primary focus of the tobacco cessation literature is on culturally and linguistically tailored behavioral treatments that are delivered in a variety of formats. Multiple studies have demonstrated efficacy for dyadic-based smoking cessation interventions for Asian American population groups; findings from dyadic interventions for this population are discussed elsewhere in this chapter (also see Table 7.7).

Table 7.12 details four individual-level RCTs focused on Asian American adults who smoke. In one, Wu and colleagues (2009) randomized a sample of lower income Chinese American adults who smoke in which the intervention group received a culturally tailored and language-matched intervention consisting of four individual motivational interviewing sessions plus 8 weeks of NRT (patches), and the comparison group received a language-matched nontailored intervention that consisted of four general health education sessions, self-help cessation materials, and the same pharmacotherapy. Compared with participants who received the control intervention, biochemically verified abstinence rates were significantly greater in those who received the culturally tailored condition both at 3 months (66.1% vs. 32.3%) and 6 months (66.7% vs. 31.7%; aOR = 7.60; 95% CI, 1.33–43.37).

Kim and colleagues (2015) conducted an RCT of eight sessions of culturally specific, language-matched individual CBT plus nicotine patch therapy compared with eight sessions of brief, nontailored, language-matched counseling plus nicotine patches among Korean American immigrants. At 12 months, biochemically verified abstinence was significantly greater in the culturally specific CBT group (38.2%) than in the nontailored brief counseling group (11.1%; OR = 4.67; 95% CI, 1.67–12.99). This study was limited by its small sample size and unmatched intensity of the interventions. Taken together, the RCTs reported by Wu and colleagues (2009) and Kim and colleagues (2015) highlight the promise of culturally specific, individual-level behavioral treatments (combined with NRT) for Chinese and Korean American adults who smoke.

Zhu and colleagues (2012) conducted an RCT among 2,227 Asian American adults in California who smoked to investigate the efficacy of telephone-based counseling among this group. An English-language counseling program was translated into Chinese, Korean, and Vietnamese, with additional culturally tailored elements integrated and delivered through the California quitline. Following stratification by language, participants were randomized into two groups to receive either six telephone counseling sessions plus printed self-help materials or self-help materials only. At 6 months, the self-reported intent-to-treat abstinence rate was significantly greater in the culturally tailored phone counseling group (16.4%) than in the self-help-only group (8.0%; p <0.001). Statistically significant differences in abstinence rates by treatment condition were also found for all three language groups. The study was limited by the self-help-only condition being a less intense intervention without an equivalent level of counseling support and by a reliance on self-reported abstinence without biochemical verification.

Table 7.12 Individual-level tobacco cessation treatment trials among Asian American people who smoke

Study | Design, population, and location | Intervention | Smoking cessation-related finding(s) | Tailoring to the population and study limitations
Wu et al. (2009) | - RCT; - Chinese American adults who smoked (n = 139), the majority of whom were male; - Recruited through community-based organization serving Chinese American people; - Primary quit smoking outcomes measured (longest endpoint):; – Biochemically verified 7-day point-prevalence abstinence at 6-month follow-up; - New York City | - Condition 1: Culturally tailored Chinese quit smoking cessation program and adapted motivational interviewing-based behavioral counseling (four sessions); intervention was adjusted according to readiness to quit smoking; - Condition 2: Usual care smoking cessation program that included four sessions in Chinese language focused on general health education, and provided self-help smoking cessation materials; - Both groups were offered 8 weeks of NRT (patches) | - Differences in biochemically verified abstinence at the 6-month follow-up were statistically significant by condition (aOR = 7.60; 95% CI, 1.33–43.37; p <0.05):; – Culturally tailored group: 66.7%; – Usual care group: 31.7%; - Usefulness of findings to understand or reduce tobacco-related health disparities:; – Compared with results from the usual care program, cessation results were promising for the culturally tailored, evidence-based tobacco cessation treatment approach; findings support the feasibility of culturally tailored smoking cessation intervention for Chinese American males who smoke | - Tailoring:; – Adapted version of motivational interviewing techniques was translated into Chinese; – Program was culturally and linguistically tailored with materials that incorporated social and cultural factors that would resonate with Chinese people who smoked; - Limitations:; – Most participants were male, which reduces the generalizability of findings for females; – ORs had wide CIs
McDonnell et al. (2011) | - RCT; - Korean American adults who smoked (n = 1,112) and lived in the United States; - Primary quit smoking outcomes measured (longest endpoint):; – 30-day continuous abstinence at 50 weeks post-enrollment; - United States | - Condition 1: Internet version of the Quitting is Winning self-help smoking cessation program was culturally tailored for Korean American people who smoked; - Condition 2: Printed version of Quitting is Winning self-help materials was mailed to the homes of participants | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Differences in abstinence rates were not statistically significant by condition (OR = 0.9; 95% CI, 0.6–1.2; p = 0.38):; – Internet version: 10.9%; – Printed version: 12.5%; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Although an online culturally tailored smoking cessation intervention for Korean American people who smoke has the potential for high reach in the community, it did not result in higher quit rates compared with a printed self-help version of the program | - Tailoring:; – Development of the Quitting is Winning smoking cessation program used principles of community-based participatory research that engaged an advisory board in the Korean American community; – Materials were translated into Korean and underwent a linguistic equivalency process; - Limitations:; – Internet intervention was underused; – Smoking abstinence was based on self-reports; no biochemical verification
Zhu et al. (2012) | - RCT; - Asian American (Chinese, Korean, Vietnamese) adults who smoked, lived in California (n = 2,227), and were seeking quitline support for quitting; - Primary quit smoking outcomes measured (longest endpoint):; – 6-month continuous abstinence; - California | - Condition 1: Six sessions of culturally tailored quitline counseling plus self-help materials on quitting smoking in preferred language; - Condition 2: Callers provided with written self-help materials on quitting smoking in their preferred language | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Differences in abstinence rates were statistically significant for the full sample and Chinese, Korean, and Vietnamese American participants by condition:; – Counseling: 16.4%; – Self-help: 8.0%; – Difference = 8.4% (95% CI, 5.7–11.1; p <0.001); - Differences in abstinence rates were statistically significant for all three language subgroups by condition:; – Chinese participants:; ○ Counseling: 14.8%; ○ Self-help: 6.0%; ○ Difference = 8.8% (95% CI, 4.4–13.2; p <0.001); – Korean participants:; ○ Counseling: 14.9%; ○ Self-help: 5.2%; ○ Difference = 9.7% (95% CI, 5.8–13.8; p <0.001); – Vietnamese participants:; ○ Counseling: 19.8%; ○ Self-help: 13.5%; ○ Difference = 6.3% (95% CI, 0.9–11.9; p = 0.023); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Findings support the efficacy of culturally tailored telephone counseling for smoking cessation among Chinese, Korean, and Vietnamese American people who smoke | - Tailoring:; – Culturally tailored counseling protocol was developed in English and translated into Chinese, Korean, and Vietnamese; - Limitations:; – No nontailored language-congruent self-help condition; – Unmatched intervention intensity between conditions; – Self-reported smoking cessation; no biochemical verification of abstinence; – Excluded people who smoked and had current psychiatric conditions, which limits the generalizability of findings for Asian American people who smoke and have mental illness
Kim et al. (2015) | - RCT; - Korean American adult immigrants who smoked (n = 109), the majority of whom were male; - Primary quit smoking outcomes measured (longest endpoint):; – Biochemically verified 12-month continuous abstinence; - Northeastern United States | - Condition 1: Culturally tailored, CBT-based individual counseling for smoking cessation (8 sessions, 40 minutes per session); - Condition 2: Usual care, which included individual counseling for smoking cessation that was not culturally tailored (8 sessions, 10 minutes per session); - Both groups were offered NRT (patches); all participants except for one received counseling in Korean language | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - The difference in abstinence rates was statistically significant by condition (OR = 4.67; 95% CI, 1.67–12.99; p <0.01):; – Culturally tailored: 38.2%; – Usual care: 11.1%; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Findings support the feasibility of conducting larger efficacy trials of culturally adapted, CBT-based smoking cessation interventions among Korean American people who smoke, particularly among those with a strong orientation to Korean culture | - Tailoring:; – Cessation intervention was culturally tailored; participant acculturation level was assessed; majority endorsed a stronger orientation to Korean culture than to American culture; - Limitations:; – Small sample pilot trial with mostly male participants, which reduces the generalizability of findings for Korean American females who smoke; unmatched intervention intensity between conditions

Notes: aOR = adjusted odds ratio; CBT = cognitive behavioral therapy; CI = confidence interval; NRT = nicotine replacement therapy; OR = odds ratio; RCT = randomized controlled trial.

McDonnell and colleagues (2011) used principles of CBPR in an RCT that compared an Internet-based self-help cessation intervention culturally tailored for Korean American adults who smoke with a written version of the intervention that was mailed to participants. Fifty weeks after enrollment, self-reported 30-day continuous abstinence was comparable between the two conditions (10.9% for Internet self-help vs. 12.5% for written self-help); quit rates were higher among participants in the Internet intervention who completed the program (26% vs. 10% in non-completers). This study was limited by overall low utilization of the Internet program and a reliance on self-reports.

#### Summary

Overall, Asian American people represent a diverse racial and national heritage group with varied rates and patterns of tobacco use and varied tobacco cessation treatment needs. Although few studies have examined the effects of evidence-based interventions among different Asian American population groups, interventions to date that have focused on these population groups have included cultural and language adaptations of interventions with primary components of behavioral counseling, counseling plus pharmacotherapy, or online self-help materials. In two small RCTs reviewed here, these culturally and linguistically specific interventions show promising results for enhanced efficacy compared with nontailored interventions. Future research is needed to strengthen the existing evidence base by addressing the methodologic limitations of the existing studies, exploring tailoring for an increased diversity of Asian population groups, and increasing understanding of pharmacotherapy outcomes in this heterogeneous group.

### Hispanic or Latino People

Hispanic or Latino people living in the United States are a heterogeneous population with a relatively low overall prevalence of smoking, but their smoking rates vary by nationality (Babb et al. 2020). The evidence shows that Hispanic or Latino American people often have a low frequency of smoking (a light daily and intermittent smoking pattern); however, the leading causes of mortality among Hispanic people are tobacco related (CDC n.d.b) and some Hispanic population groups (e.g., those living in poverty) exhibit higher risk smoking behaviors such as regular smoking over multiple years (Kristman-Valente and Flaherty 2016).

The Clinical Practice Guideline examined the effectiveness of cessation interventions for cigarette smoking among specific racial and ethnic groups and identified four RCTs among Hispanic people (Fiore et al. 2008). The review found that the nicotine patch; telephone counseling; self-help materials, including a mood management component; and tailoring have been shown to be effective in helping Hispanic people quit smoking. A subsequent meta-analysis of five studies by Webb and colleagues (2010b) (including three of the four studies in the Clinical Practice Guideline review by Fiore and colleagues [2008]) concluded that tobacco cessation interventions (including self-help materials; individual, group, and telephone counseling; and nicotine patch) increased cessation at the end of treatment (OR = 1.54; 95% CI, 1.09–2.16), but the effect of the interventions at first follow-up was not significant (OR = 1.46; 95% CI, 0.96–2.23) among three of the five studies. Additional trials published after that meta-analysis have investigated the effects of multiple treatment types in this population. Table 7.13 details five RCTs published after Webb and colleagues’ (2010b) meta-analysis that focused on cessation treatment among Hispanic adults who smoke.

Individual-level counseling interventions among Hispanic or Latino adults in the United States have been examined in several studies. For example, three RCTs included comparisons of culturally specific and nontailored interventions delivered during home visits (Borrelli et al. 2010), brief motivational enhancement versus a delayed intervention control (Cabriales et al. 2012), and intensive culturally tailored counseling versus two sessions of brief advice (Stanton et al. 2015). Findings from these three RCTs all showed low quit rates and no significant difference between treatment conditions. Each study considered the potential cultural needs of the focus population within the context of the intervention. What remains unclear are the factors that may affect quitting, such as the dose of the cultural tailoring—that is, whether the intervention components incorporated cultural tailoring at a “surface structure” level (incorporation of superficial target population characteristics that enhance intervention acceptability) or a “deep structure” level (incorporation of unique population-specific factors that influence health behaviors and outcomes) (Resnicow et al. 1999; Castro et al. 2015)—as well as study attrition and underpowered analyses.

Low-intensity self-help interventions have also been evaluated among Hispanic adults who smoke. Rodriguez-Esquivel and colleagues (2015) conducted a 2 × 2 factorial randomized experiment of self-help interventions that varied based on cultural specificity (culturally specific written educational materials vs. nontailored written educational materials) and preferred language (English vs. Spanish). Smoking cessation was significantly greater among participants who received written materials in their preferred language than it was among participants who received materials in their less preferred language. Receiving culturally tailored quit smoking materials (materials that incorporated Hispanic smoking patterns, cultural values, and norms) was not associated with increased abstinence. This study was limited by its short follow-up and a reliance on self-reports.

Table 7.13 Individual-level tobacco cessation treatment trials among Hispanic or Latino people who smoke

Study | Design, population, and location | Intervention | Smoking cessation-related finding(s) | Tailoring to the population and study limitations
Borrelli et al. (2010) | - RCT nested within a home-based asthma intervention program; - Latino adults who smoked and were caregivers (n=133), the majority of whom were female and lower income; 41.3% graduated from high school; - Latino ethnic groups represented in the trial:; – 52.2% Puerto Rican; – 22.7% Dominican American; – 10.6% Central American; – 6.0% South American; – 2.2% Mexican American; – 0.8% Cuban American; – 3.7% Other Latino ethnic group; - Primary quit smoking outcomes measured:; – Biochemically verified continuous abstinence at 2 and 3 months after treatment; - Rhode Island | - Condition 1: BAM, an intervention focused clinical guidelines for smoking cessation; - Condition 2: PAM, an intervention focused on the carbon monoxide levels of caregivers and on behavioral counseling to raise awareness of children’s exposure to secondhand tobacco smoke; materials were culturally tailored; - Both conditions received three home visits, a brief follow-up call, and a self-help manual (components in English and Spanish languages) | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Differences in continuous abstinence rates were not statistically significant by condition:; – 2 months (OR = 2.54; 95% CI, 0.91-7.10; p >0.05):; ○ BAM: 9.2%; ○ PAM: 20.5%; – 3 months (OR = 1.68; 95% CI, 0.64-4.37; p >0.05):; ○ BAM: 12.3%; ○ PAM: 19.1%; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Trial included a variety of Latino ethnic groups, which is uncommon in smoking cessation trials; – Findings, although not statistically significant, supported the benefits of culturally tailoring a quit smoking intervention for Latino caregivers who smoke | - Tailoring:; – PAM was tailored to be consistent with core values of many Latino cultures such as personalismo, familismo, and simpatia; – Behavioral counseling was delivered by a Latina health educator who was bilingual; - Limitations:; – Small sample; – Surface-level tailoring; benefits from deeper tailoring unknown; – Participants from one Northeastern state may limit generalizability to other people and settings
Cabriales et al. (2012) | - RCT; - Hispanic adults who smoked ≤10 cigarettes per day (“light smoking”) or non-daily (“intermittent smoking”) (n = 214); 88% identified as Mexican or Mexican American; - Primary quit smoking outcomes measured (longest endpoint):; – 30-day continuous abstinence at 3-month follow-up; - El Paso, Texas | - Condition 1: Individual-level behavioral counseling delivered by a health educator immediately at the time of recruitment; - Condition 2: Delayed intervention group | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Results showed no statistically significant differences in 30-day continuous abstinence (p >0.05) by condition:; – Immediate intervention: 5.6%; – Delayed intervention: 4.7%; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Low rates of cessation may be related to challenges faced by Hispanic adults residing in a U.S.-Mexico border region; – Quitting did not differ by intervention group; – Participants reported increased motivation to quit after the intervention | - Tailoring:; – Considered Hispanic culture in intervention development; – Spanish language materials and a bilingual interventionist were available; - Limitations:; – High attrition, as 107 participants in the delayed intervention group agreed to complete the 3-month follow-up assessment, but only 10 participants agreed to receive the intervention; – Reliance on self-report; no biochemical verification; – Effects may not generalize to other Latino ethnic groups; – No pharmacotherapy offered
Rodriguez-Esquivel et al. (2015) | - 2 × 2 factorial randomized experiment testing self-help materials; - Community sample of Hispanic adults who smoked and were bilingual (English and Spanish) (n = 222); - Primary quit smoking outcomes measured (longest endpoint):; – Self-reported smoking cessation at 2-week follow-up; - Florida | - Factor 1 (tailoring): Culturally tailored or standard self-help written materials on quitting smoking; - Factor 2 (preferred language): Self-help materials in English or Spanish | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Main effect of language preference: Self-reported abstinence was statistically significantly greater when materials were delivered in the preferred language (OR = 5.36; 95% CI, 1.11-25.95; p = 0.037); - No significant differences were seen in abstinence rates for the main effect of cultural specificity (OR = 3.07; 95% CI, 0.78-12.06; p = 0.109) or the interaction term (tailoring × preferred language) (OR = 4.24; 95% CI, 0.17-107.67; p = 0.381); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Hispanic adults who smoked increased smoking cessation success if they were provided with materials on quitting smoking in their preferred language; however, culturally tailored materials were not associated with increased abstinence | - Tailoring:; – Included eight dimensions of Cultural Enhancement Model that includes cultural values, beliefs, and practices shared by many Hispanic people in the United States; - Limitations:; – Short follow-up (2 weeks); – Standalone written materials; – Self-reported cessation; no biochemical verification
Stanton et al. (2015) | - RCT; - Latino adults who smoked and had HIV/AIDS (n = 302); 56% identified as Puerto Rican; - Primary quit smoking outcomes measured (longest endpoint):; – Biochemically verified 7-day point-prevalence abstinence at 12-month follow-up; - Northeastern United States | - Condition 1 (enhanced usual care): Behavioral counseling in person (2 visits) and by phone (1 call) plus self-help materials; - Condition 2 (Project Aurora): Enhanced usual care plus culturally tailored behavioral counseling, tailored self-help materials and videos, two additional in-person sessions, two booster phone calls, and optional buddy support; - Both groups were offered 8 weeks of NRT (patches); - All materials and interventions were available in both Spanish and English languages | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Abstinence rates at the 12-month follow-up did not differ significantly by condition (p = 0.93):; – Project Aurora: 6%; – Enhanced usual care: 7%; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Latino adults who smoke and have HIV/AIDS could benefit equally from the enhanced standard care and culturally tailored interventions; culturally tailored tobacco cessation treatment components did not contribute to better cessation outcomes | - Tailoring:; – Project Aurora included multiple layers of cultural tailoring; for example, it hired Latino staff to deliver the intervention, and intervention materials incorporated the roles of culture, family, and values related to the country of origin; - Limitations:; – Conditions were not matched in terms of treatment intensity; – NRT use was poorly documented
Simmons et al. (2022); Study design described in Medina-Ramirez et al. (2019) | - Two-arm, parallel RCT; - Hispanic adults who smoked ≥5 cigarettes per week and preferred educational health materials in Spanish (n = 1,417); - Latino ethnic groups represented in the trial:; – 33.7% Mexican American; – 22.3% Cuban; – 16.6% Puerto Rican; – 8.9% South American; – 6.1% Central American; – 2.6% Dominican; – 1.9% Other Latino ethnic group; – 7.9% More than one ethnic group; - Primary quit smoking outcomes measured:; – 7-day point-prevalence abstinence at four assessment points; – 30- and 90-day point-prevalence abstinence were secondary smoking outcomes; - United States and Puerto Rico | - Condition 1 (usual care): Spanish-language booklet developed by NCI; - Condition 2 (LDC): Spanish language translation and cultural adaptation of Forever Free: Stop Smoking for Good, a self-help intervention comprised of 11 booklets and 9 pamphlets mailed over 18 months (initial mailing upon randomization); - Intervention materials were distributed by postal mail, with the option of receiving additional electronic versions via email; - Assessments for both arms were conducted every 6 months for 2 years | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Overall, abstinence rates were higher in the LDC group than they were in the usual care group (p <0.001):; – Logistic regression analysis revealed that abstinence rates in the LDC group were higher than in the usual care group at 24 months (OR = 1.54; 95% CI, 1.18-2.02; p = 0.002) and at 6, 12, and 18 months (all p values <0.001); – Logistic regression analysis revealed that 30- and 90-day abstinence rates at 24 months were higher in the LDC group than the usual care group; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Sex was a significant moderator of 7-day abstinence; – Higher abstinence rates for LDC were observed for men at all follow-up points and for women at only 6- and 12-months follow-up | - Tailoring:; – A booklet was included for family and friends to address familism (i.e., the importance of family support); – Added a phone call to address a desire for personal contact; - Limitations:; – Used self-reported information about smoking status; – Participants responded to recruitment efforts that advertised smoking cessation materials, so it is unclear how people unmotivated to quit smoking may have responded; – Because LDC was delivered in monthly installments and included a 10-minute telephone call, the impact of more frequent contacts (vs. the intervention content) is unclear

Notes: BAM = Behavioral Activation Model; CI = confidence interval; LDC = Libre del Cigarillo; NCI = National Cancer Institute; NRT = nicotine replacement therapy; OR = odds ratio; PAM = Precaution Adoption Model; RCT = randomized controlled trial.

In contrast, Simmons and colleagues (2022) found that the culturally tailored Spanish-language Libre del Cigarrillo (LDC) self-help intervention, which consisted of 11 booklets and 9 pamphlets mailed over 18 months, was associated with greater 7-day point-prevalence abstinence at 24 months (OR = 1.54; 95% CI, 1.18–2.02) compared with a 40-page Spanish-language self-help booklet developed by NCI, which was mailed upon randomization (Medina-Ramírez et al. 2019). Interestingly, sex was a significant moderator of 7-day abstinence. Higher LDC abstinence rates were observed for men at all follow-up points (6, 12, 18, and 24 months) and for women only at 6 and 12 months. The authors noted that they could not disaggregate the potential effect of frequent contacts for LDC (mailed in nine separate installments) and its intervention content.

#### Summary

In summary, based on the few studies conducted to date, it remains generally unclear whether tailored tobacco cessation interventions for U.S. Hispanic or Latino adults are more effective than nontailored interventions. While the evidence suggests that self-help materials for Hispanic or Latino adults are more effective when they are in an individual’s preferred language, only one study specifically tested preferred language materials (Rodriguez Esquivel et al. 2015). Moreover, with some exceptions, the samples in the reviewed studies generally did not account for the wide diversity of smoking patterns and nationalities represented within this ethnic group. Culturally tailored intervention approaches among Hispanic or Latino adults who smoke have emphasized individual cultural values—for example, familismo (dedication, commitment, and loyalty to family) and respeto (respect) (Wetter et al. 2007; Borrelli et al. 2010; Simmons et al. 2022)—and may have paid less attention to other potentially influential factors, such as culturally congruent recruitment and retention strategies, access to care, different communication patterns across Hispanic or Latino nationalities, acculturation, stress related to being a member of a minoritized racial and ethnic group, discrimination, underemployment, insurance status, immigration status, and fear of deportation.

Additional research is also needed on programs and interventions, such as contingency management, that could increase the usage of cessation medication among Hispanic or Latino adults who smoke (CMS 2017). In addition, rigorous research is warranted to better address the needs of this priority population who, in general, have lower rates of being advised by a healthcare professional to quit and less use of cessation treatment than non-Hispanic White adults (Babb et al. 2020). Finally, research is warranted among specific population groups of Hispanic adults, such as Puerto Rican people who have a higher prevalence of cigarette smoking and daily smoking than other Hispanic population groups and those who self-identify as Mexican who have a lower prevalence of cessation treatment use than non-Hispanic White adults (Babb et al. 2020).

### Minoritized Sexual Orientation and Gender Identity Groups

Minoritized sexual orientation and gender identity groups are highly diverse population groups with different identities. Three recent reviews of tobacco cessation treatments among minoritized sexual orientation and gender identity population groups that included both peer-reviewed and gray literature concluded that interventions to date have shown evidence of effectiveness. However, most of the studies did not have a control group or biochemically validated smoking status, which may limit the validity of the review articles’ findings (Lee et al. 2014; Baskerville et al. 2017; Berger and Mooney-Somers 2017).

Lee and colleagues (2014) found that 9 of the 14 clinical interventions they reviewed were cessation groups (with or without NRT) and concluded that group cessation curricula tailored to LGBT communities showed evidence of effectiveness for cessation but cautioned that the reach of these programs was very limited. They also concluded that the evidence suggests that evidence-based, nontailored tobacco cessation treatments work as well at increasing successful quitting among LGBT people as heterosexual people (Lee et al. 2014). Two recent studies also observed no differences in cessation outcomes between LGBT and non-LGBT adults for nontailored cessation programs (Table 7.14). One study was among young adults enrolled in either a nontailored 90-day Facebook group intervention or referred to NCI’s Smokefree.gov (Vogel et al. 2019). The other study was among adults enrolled in either a nontailored web-based cessation intervention grounded in acceptance and commitment therapy or NCI’s Smokefree.gov (Heffner et al. 2020).

All three review articles concluded that more research on the effectiveness of cessation treatments tailored for minoritized sexual orientation and gender identity groups is needed (Lee et al. 2014; Baskerville et al. 2017; Berger and Mooney-Somers 2017). For example, some studies that measure LGBTQI+ disparities do not include gender identity, and gaps exist in research about tailoring treatments for specific segments of the LGBTQI+ community despite ample evidence of intra-community disparities. Also, Baskerville and colleagues (2017) noted that most studies in both their and Berger and Mooney-Somers (2017) reviews were culturally tailored. Berger and Mooney-Somers (2017) stated that the most effective cultural modifications may be employing LGBT facilitators, discussion of LGBT-specific triggers, and discussion of hormone replacement therapy and smoking.

Table 7.14 Individual-level tobacco cessation treatment trials among people from minoritized sexual orientation and gender identity groups who smoke

Study | Design, population, and location | Intervention | Smoking cessation-related finding(s) | Tailoring to the population and study limitations
Matthews et al. (2019) | - Two-group randomized trial; - Adults, 18-65 years of age, who smoked ≥4 days per week, had CO levels of >8 ppm, scored >5 on a 10-point Likert scale for desire to quit, and self-identified as LGBT (n = 345); - Participants were recruited from bars, community events, festivals, street-intercepts, flyers, electronic health records, and provider and participant referrals; - Primary quit-smoking outcomes measured:; – Biochemically verified 7-day point-prevalence abstinence at 1, 3, 6, and 12 months following baseline; - Lakeview site of Howard Brown Health, which is an LGBT-serving federally qualified healthcare center in Chicago, Illinois | - Condition 1, Courage to Quit treatment (n = 173):; – A semi-structured and manualized smoking cessation intervention of six weekly sessions starting 2 weeks before the designated quit date and proceeding 4 weeks after the quit date.; – Treatment modules included a progression of topics incorporating evidence-based behavioral, cognitive, and motivational smoking cessation strategies, as outlined in the U.S. Public Health Service’s Clinical Practice Guidelines for Treating Tobacco Use and Dependence; - Condition 2, Courage to Quit treatment culturally tailored for people who are LGBT (n =172):; – Cultural tailoring was based on an iterative process of literature reviews, community engagement (focus groups), and pilot testing to adapt the Courage to Quit intervention; - All participants were offered NRT | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Analyses adjusted for race and ethnicity, age, gender identity, sexual orientation, level of readiness to quit, and use of menthol cigarettes; - Rates of quitting smoking did not differ significantly between treatment groups in unadjusted and adjusted analyses for all time points (e.g., 12-month follow-up: adjusted OR = 0.70; 95% CI, 0.26-1.91; p = 0.484); - Biochemically verified 7-day point-prevalence reported abstinence rates by follow-up:; – 1-month follow-up:; ○ Condition 1 = 33.5% quit; ○ Condition 2 = 30.2% quit; – 3-month follow-up:; ○ Condition 1 = 23.1% quit; ○ Condition 2 = 19.2% quit; – 6-month follow-up:; ○ Condition 1 = 30.1% quit; ○ Condition 2 = 21.5% quit; – 12-month follow-up:; ○ Condition 1 = 24.3% quit; ○ Condition 2 = 20.3% quit | - Tailoring:; – Culturally tailored elements included culturally specific determinants of smoking (e.g., beliefs, norms); culturally informed and relevant advice and support; and use of images, color, pictures, evidence, and language that were relevant to the group and their cultural values, beliefs, and behaviors; - Limitations:; – Treatment facilitators were not blinded to treatment conditions, and intervention fidelity was not independently assessed; – 6- and 12-month abstinence were biochemically verified for only a few participants; – Generalizability may be limited to LGBT-serving federally qualified healthcare centers
Vogel et al. (2019) | - RCT; - Young adults, 18-25 years of age, who smoked ≥3 days per week and used Facebook ≥4 days per week) (n = 500); - Participants were recruited from Facebook using a paid ad campaign that was conducted between October 2014 and July 2015; - Primary quit-smoking outcomes measured:; – 7-day point-prevalence abstinence at 3, 6, and 12 months following baseline; - Nationwide (United States) recruitment | - Condition 1 (control): Referral (n = 249) to Smokefree.gov, which was developed and is managed by NCI; - Condition 2 (treatment): Participation in the Tobacco Status Project, a 90-day intervention conducted for young adults on Facebook (n = 251):; – Participants were assigned to private Facebook groups that were tailored to their readiness to quit smoking; – Facebook posts were designed based on the U.S. Clinical Practice Guidelines and the Transtheoretical Model skills for smoking cessation and were posted once a day for 90 days; – Participants had the opportunity to participate in live, online counseling sessions.; – Facebook groups were randomly assigned to receive a monetary incentive for commenting on posts (daily, weekly, monthly, or no incentive, for a maximum of $90); - All participants were compensated with a $20 gift card for completing each survey (baseline and 3, 6, and 12 months) | - Secondary analyses compared outcomes between young adults with SGM identities and young adults with non-SGM identities; - After controlling for study condition, abstinence from smoking over the 12-month follow-up period did not differ significantly between SGM and non-SGM groups (OR = 0.95; 95% CI, 0.59-1.52; p = 0.83); - Seven-day point-prevalence abstinence rates by follow-up:; – 3-month follow-up:; ○ SGM = 8.6% quit; ○ Non-SGM = 11.2% quit; – 6-month follow-up:; ○ SGM = 18.8% quit; ○ Non-SGM = 15.4% quit; – 12-month follow-up:; ○ SGM = 20.0% quit; ○ Non-SGM = 21.6% quit | - Tailoring:; – No specific tailoring; however, using a digital intervention may address the participant’s comfort level with interactions, privacy concerns, and reach to geographically underserved areas; - Limitations:; – Results may not generalize to age groups other than young adults
Heffner et al. (2020) | - RCT; - Adults, ≥18 years of age, who smoked ≥5 cigarettes per day, were motivated to quit within the next 30 days, had access to the Internet and e-mail, and had never used the control and treatment interventions (n = 2,637); - Participants were recruited from diverse sources, both online (ads, survey panels, and search engine results) and offline (earned media, referrals from family members and friends, mailings to members of Kaiser Permanente Washington); targeted recruitment sought 25% representation from minoritized racial and ethnic populations; - Primary quit-smoking outcomes measured:; – 30-day point prevalence abstinence (PPA) at 12 months | - Condition 1 (control): Referral (n = 173) to Smokefree.gov, which was developed and is managed by NCI; - Condition 2: Web-based cessation intervention grounded in acceptance and commitment therapy; - All participants had access to their assigned intervention for 12 months and received up to four intervention text messages per day for 28 days; content of the messages differed by condition but the intent was the same: to push key intervention content to participants and encourage them to use their respective web-based program; - Participants received $25 to complete surveys at 3, 6, and 12 months, with a $10 bonus if the survey was completed within 24 hours | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Secondary analysis examined differences in abstinence by SM status and across groups (bisexual, lesbian, and gay); analyses adjusted for treatment group, gender, education level, amount of smoking, depression, anxiety, any mental health condition, and number of adults in the home who smoked; - 30-day PPA did not differ significantly between SM people (19.8%) and non-SM people (22.4%) at 12 months (OR = 0.86; 95% CI, 0.62-1.20; p = 0.39).; - Quit rates did not differ across SM groups (20.6% for bisexual people and 18.9% for lesbian or gay people: OR = 1.02; 95% CI, 0.52-1.97; p = 0.96) | - Tailoring:; – No specific tailoring (although online programs may have advantages in overcoming barriers to cessation treatment among LGBT populations (see Vogel et al. (2019)); - Limitations:; – Study did not assess gender minority status (e.g., transgender, nonbinary); – Sexual orientation was assessed by a limited number of descriptors; – No biochemical verification of cessation outcomes; – Most participants were women (83%); - Generalizability may be limited to people seeking treatment and willing to use an online program
Vogel et al. (2020) | - Pilot RCT; - Young adults, 18-25 years of age, who smoked ≥1 cigarette per day ≥4 days per week, used Facebook ≥4 days per week, and self-identified as an SGM (n = 165); - Participants were recruited from Facebook using an ad campaign directed at SGM people who smoked; - Primary quit-smoking outcomes measured:; – Biochemically verified 7-day point-prevalence abstinence at 3 and 6 months following baseline; - Nationwide (United States) recruitment | - Condition 1: Participation in the Tobacco Status Project, a 90-day Facebook intervention for young adults (n = 81); - Condition 2: Participation in the Put It Out Project, a 90-day smoking cessation intervention conducted on Facebook and culturally tailored to young adults with SGM identities (n = 84); the project was developed through formative work, including online focus groups and usability testing; - For both conditions:; – Participants were assigned to private Facebook groups that were tailored to their readiness to quit smoking; – Facebook posts were designed based on the U.S. Clinical Practice Guidelines and the Transtheoretical Model skills for smoking cessation and were posted once a day for 90 days; – “The Doctor Is In”—which were weekly, 1-hour, live group chat sessions—were also included; – Participants received a monetary incentive for commenting on all or nearly all Facebook posts each month (up to $90); – Participants were compensated with a $20 gift card for completing each survey and a $20 bonus for completing all three surveys (baseline and 3 and 6 months) | - Abstinence from smoking did not differ significantly between the treatment conditions at 3 months (OR = 2.00; 95% CI, 0.48-8.28; p = 0.33) and at 6 months (OR = 3.12; 95% CI, 0.81-11.97; p = 0.08); - 7-day point-prevalence reported abstinence rates at:; – 3-month follow-up:; ○ Condition 1 = 3.7%; ○ Condition 2 = 7.1%; – 6-month follow-up:; ○ Condition 1 = 3.7%; ○ Condition 2 = 10.7% | - Tailoring:; – Included pictures of people and couples with SGM identities and symbols and terms that were meaningful to the SGM community; – Involved discussions of smoking-related topics relevant to the SGM community (e.g., targeted advertising, coping with prejudice and discrimination, and prevalence of smoking in social spaces); – The counselor introduced herself as a member of the SGM community; - Limitations:; – Abstinence could not be biochemically verified in a large portion of the participants reporting abstinence (cotinine testing did not allow for differentiation of smoking from other nicotine sources); – The sample was geographically diverse, but most participants were non-Hispanic White people, limiting generalizability to other racial and ethnic groups; – The small sample size may have limited the study’s power to detect differences in outcomes

Notes: LGBT = lesbian, gay, bisexual, and transgender; NCI = National Cancer Institute; NRT = nicotine replacement therapy; RCT = randomized controlled trial; SGM = sexual and gender minority; SM = sexual minority.

A recent study by Matthews and colleagues (2019) randomized LGBT adults to either a nontailored 6-week group treatment (Courage to Quit) or a culturally targeted LGBT version of the same treatment and observed no difference in abstinence between the treatments (12-month abstinence: 20.3% tailored, 24.3% control, aOR=0.7; 95% CI, 0.26–1.91). The authors speculated that their setting of an LGBT-serving FQHC may have influenced study outcomes by enhancing all participants’ feelings of comfort, cohesiveness, and support in both arms of the study. Similarly, Vogel and colleagues (2020), in a pilot study of LGBT young adults, observed no differences in abstinence between a culturally tailored 90-day Facebook smoking cessation intervention (Put It Out Project) and the nontailored 90-day Facebook intervention (Tobacco Status Project) although sample size may have limited the pilot’s power to detect differences in cessation outcomes.

Berger and Mooney-Somers (2017) noted that all the studies they reviewed included gay men while two-thirds included lesbian and bisexual people. All three review articles (Lee et al. 2014; Baskerville et al. 2017; Berger and Mooney-Somers 2017) also noted a lack of studies among transgender people and Baskerville and colleagues (2017) noted a large research gap in prevention and cessation interventions for LGBTQ youth and young adults. A recent scoping review of alcohol, tobacco, and other drug treatment interventions for minoritized sexual orientation and gender identity individuals also concluded that a greater focus is needed on interventions for sexual minority women, gay men, and sexual and gender minority people of color (Kidd et al. 2022). Additional research focused on cessation among minoritized sexual orientation and gender identity population groups is warranted and should include assessments of both sexual orientation and gender identity, which will facilitate the examination of differences in cessation outcomes among different population groups and the identification of treatment components that may be particularly effective for increasing cessation (Baskerville et al. 2017; Kidd et al. 2022).

### Rural Populations

People who live in rural areas experience tobacco-related health disparities. Compared with people who smoke and live in urban areas, people in rural areas who smoke tend to have worse cessation-related outcomes when attempting to quit and are more likely to die from a tobacco-related disease (Northridge et al. 2008; Garcia et al. 2017). Quit ratios and the prevalence of a past-year quit attempt have also been significantly lower among people who smoked cigarettes and lived in rural counties than among those who lived in large central metropolitan areas (USDHHS 2020).

In one recent meta-analysis, Gupta and colleagues (2020) evaluated the impact of smoking cessation programs among populations living in Appalachia, a socioeconomically disadvantaged rural region in the eastern United States with high smoking rates and poor health outcomes. This meta-analysis of six individual or cluster randomized studies of smoking cessation interventions, including behavioral interventions (in person, web-based, and phone) and brief interventions with pharmacotherapy, found that participation in such interventions increased the probability of smoking abstinence among people in Appalachia who smoke (pooled RR = 2.33; 95% CI, 1.03–5.25). The authors noted that their results should be interpreted with caution given that substantial heterogeneity existed across the six studies, including varying definitions of smoking status and abstinence and large variations in the smoking cessation interventions and their controls.

This section reviews three rigorous trials that examined the efficacy of smoking cessation interventions for adults in rural areas who smoke that were not included in Gupta and colleagues’ (2020) meta-analysis (Table 7.15). Quitlines and mHealth-based interventions, reviewed elsewhere in this chapter, are of particular relevance to rural population reach because such interventions have characteristics that can remove or reduce barriers to access to care (such as time, transportation, or childcare), though some rural populations may have access barriers to these interventions due to limited access to Internet and broadband services (Amato and Graham 2018; USDHHS 2020). In addition, an RCT by Choi and colleagues (2016a) pertinent to rural populations is summarized in the section on American Indian and Alaska Native people in this chapter.

Zanis and colleagues (2011) conducted a smoking cessation RCT focused on young adults (18–24 years of age) who smoked who were recruited from six rural counties in Pennsylvania and randomized to receive either quitline counseling or brief in-person counseling. Abstinence rates did not differ statistically significantly across groups (abstinence at 3-month follow-up: quitline = 10.2%, in person = 19.8%; p = 0.09). However, the observed quit rates suggest that a proactive counseling intervention can engage young adults who smoke in rural areas. The study was limited by its small sample size (n = 192) and the fact that the outcomes might not generalize outside rural areas of Pennsylvania.

Table 7.15 Individual-level tobacco cessation treatment trials among people who live in rural areas and smoke

Study | Design, population, and location | Intervention | Smoking cessation-related finding(s) | Tailoring to the population and study limitations
Ellerbeck et al. (2009) | - RCT (KanQuit Study); - Adults who smoked (n = 750) and were recruited from 50 primary care practices in rural areas; - Primary quit smoking outcomes measured (longest endpoint):; – Self-reported biochemically validated (mailed salivary cotinine <15 ng/ml) 7-day point-prevalence abstinence at 24-month follow-up; - Rural Kansas | - Condition 1: Pharmacotherapy only management group:; – At baseline, participants received a health education mailing that included information about using NRT and bupropion and copies of You Can Quit Smoking and When Smokers Quit; – At 6-, 12-, and 18-months follow-up, participants received a mailing that offered free NRT or bupropion; - Condition 2: Pharmacotherapy plus MDM was offered on up to two telephone-based motivational interviewing counseling sessions every 6 months; - Condition 3: Pharmacotherapy plus high-intensity disease management (HDM) was offered on up to six motivational interviewing counseling calls every 6 months | - Intent-to-treat analysis (assumes those lost to follow-up continued smoking); - Abstinence rates did not differ significantly between conditions; - Validated odds of 7-day point-prevalence abstinence at the 24-month follow-up:; – Condition 3 (HDM) (14.8%) versus Condition 2 (MDM) (14.7%): OR = 1.00 (95% CI, 0.60–1.68, p = 0.99); – Condition 2 (MDM) and Condition 3 (HDM) versus Condition 1 (pharmacotherapy only) (13.5%): OR = 1.19 (95% CI, 0.76–1.87, p = 0.44); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Study findings support the feasibility of reaching people who smoke and live in rural areas through primary care visits and engaging them in a 24-month smoking cessation intervention | - Tailoring:; – No specific tailoring identified; - Limitations:; – Smoking cessation rates varied substantially over time and were not explained (i.e., not associated with the use of pharmacotherapy or patient discussions); – Participants were not blinded to the intervention; – Biochemically validated self-reports were available for only 58% of patients; – Pharmacotherapy was free and limited to nicotine patch and bupropion; other agents might have different results and current practices do not guarantee free medications, thus limiting generalizability; – Possible contamination between pharmacotherapy offered in the trial and pharmacotherapy available through other sources
Zanis et al. (2011) | - RCT; - Young adults, 18–24 years of age, who smoked (n = 192) and were from six rural counties in Pennsylvania; - Primary quit smoking outcomes measured (longest endpoint):; – Biochemically verified (salivary cotinine <10 ng/ml) 30-day continuous abstinence at 3-month follow-up; - Six rural counties in Pennsylvania | - Participants were randomized to two brief intervention conditions:; – Condition 1: Received advice from a health educator to quit smoking; written instructions on how to contact the Pennsylvania Tobacco Quitline; and a brief motivational interviewing session about contacting the quitline; those who contacted the quitline received free materials by mail, counseling services, and NRT; – Condition 2: Received advice from a health educator to quit smoking, a brief 5-minute intervention to encourage and motivate cessation, and an invitation to recontact the health educator for additional counseling sessions | - No significant differences in abstinence rates were observed by condition (p = 0.09):; – Condition 1: 10.2%; – Condition 2: 19.8%; - Intent-to-treat analysis was not conducted by condition, but it was conducted on the full sample: 11.4% of the sample was abstinent at the 3-month follow-up; - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – A proactive counseling intervention can engage young adults who smoke and live in rural areas in smoking cessation and can promote smoking cessation among this group of people | - Tailoring:; – No specific tailoring identified; - Limitations:; – Small sample; – Findings might not generalize to other rural populations; – Same health educator delivered both interventions; – Recruiting participants in group settings could have changed the level of services received and behaviors due to perceived social norms; – A $5 incentive was given for survey completion, which may have affected rates of participation
Byaruhanga et al. (2021) | - Three-arm RCT; - Adults who smoked cigarettes (n = 655), lived in rural and remote areas of New South Wales, Australia, and reported using tobacco products daily and having access to video communication, the internet, telephone, and e-mail; - Primary outcome: This interim analysis examined 7-day point-prevalence abstinence, prolonged abstinence, and quit attempts at 4-months post-baseline; - New South Wales, Australia | - Condition 1: Up to six sessions of video counseling, each lasting approximately 15 minutes and conducted by a trained smoking cessation advisor; - Condition 2: Up to six sessions of telephone counseling, each lasting approximately 15 minutes and conducted by a trained smoking cessation advisor; - Condition 3: Written materials in a kit from the New South Wales Quitline that was mailed to participants (minimal intervention control) | - Intent-to-treat analysis; - 7-day point-prevalence abstinence: Video: 18.9%; Telephone: 12.7%; Written: 8.9%; – A significance difference in cessation was observed between video counseling and written materials (OR = 2.39; 95% CI, 1.34–4.26; p = 0.003) but not between video counseling and telephone counseling (OR= 1.61; 95% CI, 0.95–2.72; p = 0.08); - Three-month prolonged abstinence: Video: 7.0%; Telephone: 4.4%; Written: 3.1%; – No significant differences were found between video counseling and written materials (OR = 2.33; 95% CI, 0.92–5.90; p = 0.7) and between video counseling and telephone counseling (OR=1.64; 95% CI, 0.71–3.78; p = 0.25); - Usefulness of findings to understanding or reducing tobacco-related health disparities:; – Video counseling appeared to increase 7-day point-prevalence abstinence rates among rural and remote residents compared with the use of written materials; – At 4 months post-baseline, video counseling and telephone counseling produced similar smoking cessation rates | - Tailoring:; – No specific tailoring identified; - Limitations:; – No biochemical validation of self-reported smoking cessation; – Did not measure long-term effectiveness or cost-effectiveness; – Could not assess impact of COVID-19 pandemic on utilization and effectiveness of video counseling; – Did not track whether there were multiple enrollments from the same household; – Quitline did not deliver video intervention so potential effect of integration is unknown

Notes: aOR = adjusted odds ratio; CI = confidence interval; HDM = high-intensity disease management; MDM = moderate-intensity disease management: mL = milliliter; ng = nanogram; NRT = nicotine replacement therapy; OR = odds ratio; RCT = randomized controlled trial.

Ellerbeck and colleagues (2009) conducted a cessation trial that recruited adults who smoked from rural primary care clinics in Kansas. All intervention materials for the trial were available to participants at baseline and at 6-, 12-, and 18-months follow-up. The longest follow-up was 24 months. Participants were randomized into three conditions: (1) offered free pharmacotherapy plus written self-help materials every 6 months, (2) offered free pharmacotherapy plus moderate-intensity counseling (up to two telephone encounters) every 6 months, and (3) offered free pharmacotherapy plus high-intensity counseling (up to six telephone encounters) every 6 months. Intent-to-treat analysis did not reveal any statistically detectable differences in abstinence rates by treatment condition (24-month abstinence: pharmacotherapy = 13.5%, pharmacotherapy plus moderate intensity = 14.7%, pharmacotherapy plus high intensity = 14.8%; p >0.05). Given the validated 24-month abstinence rates, the study demonstrated the feasibility of reaching rural people who smoke through primary care visits and engaging them in smoking cessation interventions.

Byaruhanga and colleagues (2021) tested real-time video counseling in a three-arm RCT (using video counseling, telephone counseling, and written materials) among 655 rural and remote residents in Australia. Though this study may not be applicable to rural U.S. population groups, it is included here due to the uniqueness of the mode of intervention delivery studied. Video counseling was found to be effective for increasing 7-day point-prevalence abstinence at 4 months post-baseline, with a significant difference in cessation observed between video counseling and written materials (OR = 2.39; 95% CI, 1.34–4.26) but not between video and telephone counseling (OR = 1.61; 95% CI, 0.95–2.72).

#### Summary

In summary, the results of RCTs show promising results related to the use of evidence-based interventions among adults living in rural areas, including one-on-one counseling delivered in person, by phone, or using video. In rural regions, participants in cessation studies were reached primarily in primary care clinics. In addition, quitlines and mHealth-based interventions promoted through mass media and other community and healthcare system efforts can address many barriers to accessing effective cessation treatment for rural populations (Amato and Graham 2018; USDHHS 2020; Byaruhanga et al. 2021). Nevertheless, more studies are needed to determine the types of cessation interventions that may be most useful in diverse rural geographic regions.

### Summary and Recommendations

Multiple population groups remain priorities for tobacco cessation interventions, including those who experience tobacco-related health disparities, those whose prevalence of tobacco use exceeds the overall national prevalence, those who have greater difficulty quitting compared with the overall population, and those that intersect with more than one of these groups. This section reviewed individual-level cessation interventions among lower SES populations, minoritized racial and ethnic groups and sexual orientation and gender identity groups, and rural populations, including interventions tailored to these groups (Fiore et al. 2008; USDHHS 2020).

Tailored interventions developed to date have generally not been associated with increased successful cessation compared with nontailored interventions among adults of lower SES, Black or African American adults, and Hispanic or Latino adults (culturally tailored and nontailored interventions appear largely equivalent in effectiveness at increasing successful quitting). Similar findings exist regarding the limited evidence base on culturally tailored interventions for minoritized sexual orientation and gender identity groups. However, evidence regarding tailored interventions is promising for increasing intermediate cessation outcomes, such as increasing quit readiness and increasing quit attempts, among Black or African American adults. Culturally tailored interventions also appear to show promise for increasing successful cessation among Asian American adults based on the few studies available for both individual and dyadic interventions, but additional research is needed to address methodologic limitations in the available literature.

Despite the importance of individual-level interventions for tobacco cessation, many research gaps remain. Although some strong evidence has been found regarding specific effective strategies for adults of lower SES (e.g., financial incentives), Black or African American adults and the aggregate group of Hispanic or Latino adults (specific behavioral and pharmacologic interventions), and the aggregate group of Asian American adults (culturally tailored interventions, including those with a dyadic component), few studies have been conducted among American Indian and Alaska Native adults and rural population groups, and no RCTs for cessation interventions were found among Native Hawaiian or Pacific Island people. Furthermore, some studies to date have been challenged by heterogeneity in priority population groups as well as methodologic limitations.

Future research on individual-level interventions in population groups that experience tobacco-related health disparities should consider several key elements to increase rigor and reproducibility. First, interventions should be guided by culturally competent models as well as community input and engagement and a recognition of the cultural diversity within many population groups (e.g., Black or African American, Asian, Hispanic, and Pacific Island population groups) (International Collaboration for Participatory Health Research 2013). Culturally specific interventions represent a promising approach for some population groups, irrespective of the type of counseling provided (e.g., motivational interviewing, CBT). However, few studies in this domain articulate a clear theoretical framework for intervention, which limits the understanding of how interventions are developed and adapted. The body of evidence related to intervention tailoring is also limited in its exploration of the “dose” or “level” of cultural tailoring that may be important—that is, tailoring at a “surface structure” level or a “deep structure” level. Future research could benefit from exploring not only the level of tailoring but components within each level (i.e., for surface structure, examining who delivers the intervention and where it is delivered, and for deep structure, examining the importance of addressing historical, environmental, and psychological influencers of health behavior) (Resnicow et al. 2002).

Second, the designs of RCTs focused on priority populations should reduce the possibility of confounding by matching the intensity of the interventions being compared across conditions in the trial (e.g., attention-control comparison groups). This design is especially important when comparing culturally specific interventions with standard programs or when channels for delivering interventions differ.

Third, research should account for heterogeneity within priority populations and consider disaggregation of data as well as investigation of interventions for population groups that may have different tobacco use behavior patterns and/or cultural perspectives. Studies should specifically test the effects of evidence-based interventions for different ethnic groups within aggregate minoritized racial and ethnic groups. Specific gaps were noted in the literature and present opportunities for future research. For example, although evidence shows the efficacy of pharmacotherapy specifically among Black or African American and Hispanic or Latino adults, there are relatively few studies. Future research should ensure the enrollment of diverse population groups, including specific attention to groups that have been historically understudied, and should report outcomes by population group. Future research should additionally address barriers to use such as access, lack of knowledge of product use, and social or cultural perceptions such as fear of addiction and perceptions of personal weakness (Webb Hooper et al. 2017b). Research about the efficacy of contingency management, or use of incentives, for various minoritized racial and ethnic groups could also be beneficial.

There is also a substantial gap in the research regarding efficacious tobacco cessation interventions for Native Hawaiian and Pacific Islander populations. Research to fill this gap needs to consider supporting quitting all forms of tobacco use, including products like betel nut with tobacco, which are more likely to be used in Guam than in other parts of the United States. Funding for future research in this area needs to account for the wide geographic distribution of people with heritage in the Pacific Islands.

Another notable gap area is research regarding intervention engagement, particularly with respect to minimizing attrition in interventions. Future research should focus on not only improving reach to priority populations, but also on improving cessation intervention engagement throughout the duration of the intervention. Studies are also needed to understand the social and structural determinants of participation in research studies and how these factors influence successful cessation for each type of intervention. The influence (positive and negative) of social and structural factors is also critical to better understanding intervention engagement, intervention efficacy, and cessation behaviors more generally. Future research on cessation interventions for specific population groups could focus on how addressing and/or incorporating these factors into interventions may impact efficacy and engagement.

Finally, some priority populations have variations in tobacco use behaviors (e.g., light and intermittent smoking) and tobacco products used (e.g., mentholated products, e-cigarettes, cigars, smokeless tobacco) that are not well addressed by the current evidence base for tobacco use and dependence treatment. Future research should focus on filling these gaps, with a particular focus on products and use behaviors with high prevalence in priority populations.

The next phase of intervention research to address tobacco-related health disparities should include research regarding intervention dissemination, implementation, scalability, and sustainability. Such research has the potential to support systems change (e.g., all health insurance plans eventually covering smoking cessation services with no barriers to accessing them) in the provision of tobacco cessation treatment for priority populations. Such research could also increase reach to priority populations and could be used to scale up interventions at the population level. Efficacious interventions should be widely available, easily accessed, and delivered in a person’s preferred language. Given the urgent need to reduce tobacco-related health disparities, it is critical that interventions that show positive effects be disseminated into communities and settings with high need. Clinical settings and population-level treatment interventions (e.g., quitlines) remain prime opportunities for reaching and engaging priority populations; research opportunities related to these topics are discussed elsewhere in this chapter.

Strategies could also be identified for the successful integration of tobacco cessation interventions into other contexts that have frequent contact with priority populations but seldom address tobacco, such as United Way 211 centers or centers that provide services as part of the Special Supplemental Nutrition Program for Women, Infants, and Children (WIC). Finally, as population-level and regulatory measures (e.g., flavor restrictions, nicotine reduction standards, smokefree policies) advance commercial tobacco control at local, state, and national levels, it is critical to identify the ideal combination of cessation-related strategies that best support the public health and health equity potential of such actions.

## Summary of the Evidence

Multiple tobacco control policies and practices—implemented at the federal, tribal, territorial, state, community, organizational, interpersonal, and individual levels—can prevent and reduce tobacco use and exposure to secondhand tobacco smoke, increase access to tobacco cessation treatment, and increase successful cessation. This chapter summarizes the evidence on tobacco control policies and practices that can, or have the potential to, reduce tobacco use and exposure to secondhand tobacco smoke and increase cessation among priority populations experiencing disparities in the United States. The extent to which certain types of interventions close the disparities gaps in tobacco use and tobacco-related health outcomes is an important area for future research.

Many of the interventions reviewed are evidence-based strategies that prevent or reduce tobacco use in the general population (e.g., smokefree policies, price increases), but these strategies often have not been equitably implemented (e.g., comprehensive in terms of geographic reach and without exemptions). Equitable, nondiscriminatory enforcement of evidence-based tobacco prevention and control policies, as described in Box 8.1 in Chapter 8, is also important to help advance health equity. Despite evidence of the effectiveness of the strategies described in this chapter, generally, more research needs to be specifically focused on the intended and unintended impact of these interventions on population groups experiencing health disparities. In some cases, it may be appropriate to tailor programmatic activities to better address tobacco-related health disparities among certain population groups. Rigorous evaluation of such tailored programs is critical to determine their effectiveness and to identify the most effective implementation strategies.

This chapter has reviewed several instances where new approaches have been shown to be helpful in driving tobacco use prevention and cessation; additional research could help further identify and evaluate the effectiveness of new or tailored interventions for specific population groups. Community-engaged participatory research in affected communities can be particularly helpful in identifying and measuring the impact of policy and programmatic interventions to address the tobacco-related disparities borne by community members, as well as effective policy development, implementation, and enforcement practices.

The effectiveness of some interventions to reduce disparities may vary based on the population demographics of the jurisdiction, characteristics of or type of community (e.g., rural, urban, or suburban), legal and political landscape, and other factors. As with other evidence-based tobacco control interventions that have been adopted, a combination of complementary interventions is expected to accelerate progress in addressing tobacco-related disparities more than a single strategy implemented alone. Additionally, combining complementary strategies, including those with broad reach and impact and those with specific reach to priority population groups, may have the greatest potential to maximize public health impact. This includes assuring that effective whole-population interventions—such as price increases and barrier-free cessation services—equitably reach population groups at greatest need and complementing those where necessary with focused interventions to population groups who still may experience disparities.

Most people initiate tobacco product use as youth, regardless of characteristics such as race or ethnicity, sexual orientation, gender identity, geographic location, or mental health status. Given this fact and the rapidly changing tobacco product market in the United States, continued research is needed to further inform future efforts and to understand how policies and programs aimed at reducing youth initiation impact different population groups.

Tobacco-related disparities can also be addressed by increasing access to comprehensive and barrier-free tobacco cessation services and eliminating social and structural barriers to obtaining cessation treatment services. This includes addressing social determinants of health (including transportation, food security, housing security, financial barriers) as an integrated part of an intervention approach, rather than limiting inclusion of these elements to documentation of their impact on program participation and cessation outcomes. Availability, accessibility, and promotion of cessation services are critical to maximizing the impact and equitable implementation of all tobacco control policies. It is strongly recommended that cessation services be accessible and promoted when implementing tobacco-related policies and that the effects of tobacco control policies on all populations, including priority populations, continue to be evaluated. Appropriate surveillance systems should be used to monitor reductions in tobacco-related disparities and to better understand which complementary interventions may be needed to further reach specific populations.

The evidence demonstrates that the tobacco industry has successfully lobbied in favor of preemption as a policy tool to block or override local, and sometimes state, tobacco control policies aimed at protecting public health. This can pose a significant obstacle to enacting innovative and effective measures to address tobacco-related health disparities. Community engagement—and authority—is necessary to achieve and accelerate progress in health equity. Additional research is recommended to evaluate the impact of preemption on tobacco-related health disparities and determine the best methods for communicating those impacts to affected communities and decision makers.

## Conclusions

1. Preemption at the federal and state levels can pose a significant obstacle for pursuing innovative policies to advance tobacco-related health equity and limits the ability of population groups that experience disparities to benefit from proven tobacco control interventions.
2. The evidence is sufficient to infer that comprehensive smokefree laws that apply to all indoor areas of public places and workplaces, including casinos, as well as smokefree policies for multi-unit housing would reduce disparities in smokefree protections and reduce exposure to secondhand tobacco smoke if fully and equitably adopted, implemented, and enforced.
3. Reducing nicotine in cigarettes and other combustible tobacco products to minimally addictive or nonaddictive levels should reduce tobacco use among many population groups experiencing tobacco-related disparities.
4. The evidence is sufficient to infer that policies that prohibit the sale of flavored tobacco products reduce sales of tobacco products and can reduce tobacco use. Eliminating the sale of flavored tobacco products, including flavored cigars, should also reduce tobacco use among groups experiencing disparities in tobacco use, especially if the policies are comprehensive and equitably implemented.
5. The evidence is sufficient to infer that policies that prohibit the sale of menthol cigarettes reduce the sale of cigarettes and increase smoking cessation. Given the disproportionate burden of menthol cigarette use among some population groups, removing menthol cigarettes from the marketplace should also reduce disparities in tobacco initiation, nicotine dependence, cessation success, and tobacco-related health outcomes, especially if policies are comprehensive and equitably implemented.
6. Policies that regulate the location of and reduce the number of tobacco retailers in neighborhoods with a high proportion of lower income, Black, or Hispanic people could help reduce disparities in retailer density, exposure to tobacco product advertisements and displays, and sales and use of tobacco products.
7. The evidence is sufficient to conclude that increases in tobacco product prices will reduce tobacco use to a greater extent among people of lower SES than they do for people of higher SES. Youth are especially price-sensitive, and price increases could help reduce tobacco use among people from all population groups at the age when they are most likely to begin smoking.
8. The evidence is sufficient to infer that quitlines can increase access to cessation treatments among population groups affected by tobacco-related disparities, particularly when quitline promotion and services are developed, delivered, and evaluated with attention to their reach and relevance to these groups.
9. The evidence is sufficient to infer that mass media countermarketing campaigns are effective at increasing quit attempts among many population groups affected by tobacco-related disparities, particularly when designed and delivered with attention to reach and relevance to these groups. However, it remains unclear if campaigns designed specifically for a single focus population are more or less effective at decreasing disparities in initiation or cessation than campaigns designed for multiple focus populations.
10. Cultural tailoring of cessation interventions (versus nontailored interventions) shows promise for increasing quitting readiness and quit attempts among African American adults and for increasing successful quitting among Asian American adults, though tailoring may not increase long-term cessation among African American adults.
11. The evidence is suggestive, but not sufficient, to conclude that incentives paired with cessation treatments increase smoking cessation among populations with lower socioeconomic status.
12. As additional research is undertaken to advance understanding of the impacts of tobacco control interventions—including cessation, media campaign, and policy interventions—on health disparities, extra considerations should be taken to ensure that such research is designed to allow for the examination of the impact of interventions among populations experiencing health disparities (e.g., ensuring enrollment of diverse populations, oversampling of population groups, attention to sample recruitment and retention, and community-engaged participatory research approaches).

## References

94th St. Grocery Corp. v. N.Y.C. Board of Health, 685 F.3d 174 (2nd Cir. 2012).
Abdel Magid HS, Halpern-Felsher B, Ling PM, Bradshaw PT, Mujahid MS, Henriksen L. Association between density and proximity of tobacco retail outlets with smoking: a systematic review of youth studies. Journal of Adolescent Health 2020;66(4):423–30.
Abrams DB, Graham AL, Levy DT, Mabry PL, Orleans CT. Boosting population quits through evidence-based cessation treatment and policy. American Journal of Preventive Medicine 2010;38(3 Suppl):S351–S363.20176308
Adelman C. Kurt Lewin and the origins of action research. Educational Action Research 1993;1(1):7–24.
Agency for Healthcare Research and Quality. 2021 National Healthcare Quality and Disparities Report. Rockville (MD): Agency for Healthcare Research and Quality, 2021. AHRQ Pub. No. 21(22)-0054-EF.
Ahluwalia JS, Okuyemi K, Nollen N, Choi WS, Kaur H, Pulvers K, Mayo MS. The effects of nicotine gum and counseling among African American light smokers: a 2 × 2 factorial design. Addiction 2006;101(6):883–91.16696632
Ahuja N, Kedia SK, Dillon PJ, Jiang Y, Yu X. Perception and intention of using less harmful and less addictive hypothetical modified risk tobacco products among never tobacco users in the united states. Addictive Behaviors 2021;122:107016.34147711
Ajzen I. From intentions to actions: a theory of planned behavior. In: Kuhl J, Beckmann J, editors. Action Control. Berlin (Germany): Springer, 1985:11–39.
Akl E, Ward K, Bteddini D, Khaliel R, Alexander A, Loutfi T, Alaouie H, Afifi R. The allure of the waterpipe: a narrative review of factors affecting the epidemic rise in waterpipe smoking among young persons globally. Tobacco Control 2015;24(Suppl 1):S13–S21.
Al-Shawaf M, Grooms KN, Mahoney M, Buchanan Lunsford N, Lawrence Kittner D. Support for policies to prohibit the sale of menthol cigarettes and all tobacco products among adults, 2021. Preventing Chronic Disease 2023;20:E05.36729702
Alamar B, Glantz S. Authors’ response to Mr. Pakko. Tobacco Control 2006;15(1):69.
Alaniz K, Christiansen B, Stewart K, Sullivan TE, Khalil L, Fiore MC. Helping low income pregnant women quit smoking: improving the First Breath program. WMJ 2019;118(3):120–5.31682747
Alexander LA, Crawford T, Mendiondo MS. Occupational status, work-site cessation programs and policies and menthol smoking on quitting behaviors of U.S. smokers. Addiction 2010;105(Suppl 1):S95–S104.
Ali FRM, Al-Shawaf M, Wang TW, King BA. U.S. adults’ attitudes toward lowering nicotine levels in cigarettes. American Journal of Preventive Medicine 2019;57(3):403–7.31303387
Ali FRM, Neff L, Wang X, Hu SS, Schecter A, Mahoney M, Melstrom PC. Tobacco-free pharmacies and U.S. adult smoking behavior: evidence from CVS Health’s removal of tobacco sales. American Journal of Preventive Medicine 2020;58(1):41–9.31761514
Allen JA, Duke JC, Davis KC, Kim AE, Nonnemaker JM, Farrelly MC. Using mass media campaigns to reduce youth tobacco use: a review. American Journal of Health Promotion 2015;30(2):E71–E82.25372236
Allwright S. The impact of banning smoking in workplaces: what are the early effects? Applied Health Economics and Health Policy 2008;6(2–3):81–92.19231902
Amato MS, Graham AL. Geographic representativeness of a web-based smoking cessation intervention: reach equity analysis. Journal of Medical Internet Research 2018;20(10):e11668.30355557
Ambrose BK, Rostron BL, Johnson SE, Portnoy DB, Apelberg BJ, Kaufman AR, Choiniere CJ. Perceptions of the relative harm of cigarettes and e-cigarettes among U.S. youth. American Journal of Preventive Medicine 2014;47(2 Suppl 1):S53–S60.25044196
American College Health Association. Position statement on tobacco on college and university campuses. Journal of American College Health 2012;60(3):266–7.22420706
American Lung Association. Leading public health groups support efforts to repeal tobacco preemption in Florida, November 22, 2021; <https://www.lung.org/media/press-releases/florida-2021-tobacco-preemption-repeal-statement>; accessed: July 7, 2022.
American Lung Association. Indepth: an alternative to suspension or citation, 2022; <https://www.lung.org/quit-smoking/helping-teens-quit/indepth>; accessed: December 15, 2022.
American Lung Association. State rankings, 2023; <https://www.lung.org/research/sotc/state-grades/state-rankings>; accessed: March 26, 2023.
American Lung Association. State “smoker protection” laws, n.d.; <https://www.lung.org/policy-advocacy/tobacco/slati/appendix-f>; accessed: July 13, 2022.
American Nonsmokers’ Rights Foundation. 100% Smokefree U.S. Hospital Campuses and Psychiatric Facilities, January 1, 2023a; <https://no-smoke.org/wp-content/uploads/pdf/smokefreehealthcare.pdf>; accessed: August 10, 2023.
American Nonsmokers’ Rights Foundation. Colleges: smokefree colleges and universities continue to grow in popularity, April 1, 2023b; <https://no-smoke.org/at-risk-places/colleges/#:~:text=Most%20local%20and%20state%20smokefree,in%20their%20smoke-free%20workplace%20laws>; accessed: May 19, 2023.
American Nonsmokers’ Rights Foundation. Taking Local Action for Smokefree Air, 2004; <https://nonsmokersrights.org/sites/default/files/2018-03/takingaction.pdf>; accessed: April 15, 2020.
American Nonsmokers’ Rights Foundation. Steps for Enacting a Smokefree College Campus Policy, 2009; <https://no-smoke.org/wp-content/uploads/pdf/steps-for-enacting-a-smokefree-college-campus-policy.pdf>; accessed: April 15, 2020.
American Nonsmokers’ Rights Foundation. States and Municipalities with Laws Regulating Use of Electronic Cigarettes as of October 1, 2021, 2021; <https://no-smoke.org/wp-content/uploads/pdf/ecigslaws.pdf>; accessed: October 28, 2021.
American Nonsmokers’ Rights Foundation. Percent of Population Covered by 100% Smokefree Non-Hospitality Workplace, Restaurant, and Bar Laws in Effect as of April 1, 2020, 2022a; <https://no-smoke.org/wp-content/uploads/pdf/WRBPercentMap.pdf>; accessed: July 13, 2022.
American Nonsmokers’ Rights Foundation. Summary of 100% Smokefree State Laws and Population Protected by 100% U.S. Smokefree Laws, July 1, 2022b; <https://no-smoke.org/wp-content/uploads/pdf/SummaryUSPopList.pdf>; accessed: July 11, 2022.
American Nonsmokers’ Rights Foundation. U.S. 100% Smokefree Laws in Non-Hospitality Workplaces and Restaurants and Bars, July 1, 2022c; <https://no-smoke.org/wp-content/uploads/pdf/WRBLawsMap.pdf>; accessed: August 1, 2022.
American Nonsmokers’ Rights Foundation. U.S. Laws for 100% Smokefree Multi-Unit Housing, July 1, 2022d; <https://no-smoke.org/wp-content/uploads/pdf/smokefreemuh.pdf>; accessed: July 10, 2022.
American Nonsmokers’ Rights Foundation. Smokefree and Tobacco-Free U.S. and Tribal Colleges and Universities, April 1, 2023; <https://no-smoke.org/wp-content/uploads/pdf/smokefreecollegesuniversities.pdf>; accessed: June 21, 2023.
American Nonsmokers’ Rights Foundation. Lists & maps: smokefree lists and maps, n.d.; <https://no-smoke.org/materials-services/lists-maps/>; accessed: August 30, 2023.
Amrock SM, Lee L, Weitzman M. Perceptions of e-cigarettes and noncigarette tobacco products among U.S. youth. Pediatrics 2016;138(5):e20154306.27940754
An LC, Schillo BA, Kavanaugh AM, Lachter RB, Luxenberg MG, Wendling AH, Joseph AM. Increased reach and effectiveness of a statewide tobacco quitline after the addition of access to free nicotine replacement therapy. Tobacco Control 2006;15(4):286–93.16885577
Anand V, McGinty KL, O’Brien K, Guenthner G, Hahn E, Martin CA. E-cigarette use and beliefs among urban public high school students in North Carolina. Journal of Adolescent Health 2015;57(1):46–51.
Anastasiou E, Feinberg A, Tovar A, Gill E, Ruzmyn Vilcassim MJ, Wyka K, Gordon T, Rule AM, Kaplan S, Elbel B, . Secondhand smoke exposure in public and private high-rise multiunit housing serving low-income residents in New York City prior to federal smoking ban in public housing, 2018. Science of the Total Environment 2020;704:135322.31787288
Anderson CM, Cummins SE, Kohatsu ND, Gamst AC, Zhu S-H. Incentives and patches for Medicaid smokers: an RCT. American Journal of Preventive Medicine 2018;55(6 Suppl 2):S138–S147.30454668
Anderson DR, Horn S, Karlan D, Kowalski AE, Sindelar JL, Zinman J. Evaluation of combined financial incentives and deposit contract intervention for smoking cessation: a randomized controlled trial. Journal of Smoking Cessation 2021;2021:6612505.34306224
Andrews JO, Mueller M, Dooley M, Newman SD, Magwood GS, Tingen MS. Effect of a smoking cessation intervention for women in subsidized neighborhoods: a randomized controlled trial. Preventive Medicine 2016;90:170–6.27423320
Anger WK, Elliot DL, Bodner T, Olson R, Rohlman DS, Truxillo DM, Kuehl KS, Hammer L, Montgomery D. Effectiveness of Total Worker Health interventions. Journal of Occupational Health Psychology 2015;20(2):226–47.25528687
Angst M, Platcha A, Miller M. ‘Heavy hit’ or ‘major milestone’? California’s flavored tobacco ban begins with mixed reviews. The Sacramento Bee, December 21, 2022; <https://www.sacbee.com/news/politics-government/capitol-alert/article270285072.html>; accessed: November 21, 2023.
Anthony J, Goldman R, Rees VW, Frounfelker RL, Davine J, Keske RR, Brooks DR, Geller AC. Qualitative assessment of smoke-free policy implementation in low-income housing: enhancing resident compliance. American Journal of Health Promotion 2019;33(1):107–17.29772910
Apelberg BJ, Feirman SP, Salazar E, Corey CG, Ambrose BK, Paredes A, Richman E, Verzi SJ, Vugrin ED, Brodsky NS, . Potential public health effects of reducing nicotine levels in cigarettes in the United States. New England Journal of Medicine 2018;378(18):1725–33.29543114
Asare S, Majmundar A, Westmaas JL, Bandi P, Xue Z, Jemal A, Nargis N. Association of cigarette sales with comprehensive menthol flavor ban in Massachusetts. JAMA Internal Medicine 2022;182(2):231–4.34982100
Asch DA, Muller RW, Volpp KG. Conflicts and compromises in not hiring smokers. New England Journal of Medicine 2013;368(15):1371–3.23534547
Athar H, Chen Z, Contreary K, Xu X, Dube SR, Chang M-H. Impact of increasing coverage for select smoking cessation therapies with no out-of-pocket cost among the Medicaid population in Alabama, Georgia, and Maine. Journal of Public Health Management and Practice 2016;22(1):40–7.26131658
Atkin CK, Freimuth V. Formative evaluation research in campaign design. In: Rice RE, Atkin CK, editors. Public Communication Campaigns. 3rd ed. Thousand Oaks (CA): Sage, 2001:125–45.
Atske S, Perrin A. Home broadband adoption, computer ownership vary by race, ethnicity in the U.S., July 16, 2021; <https://www.pewresearch.org/fact-tank/2021/07/16/home-broadband-adoption-computer-ownership-vary-by-race-ethnicity-in-the-u-s/>; accessed: July 19, 2021.
Audrain-McGovern J, Rodriguez D, Pianin S, Alexander E. Initial e-cigarette flavoring and nicotine exposure and e-cigarette uptake among adolescents. Drug and Alcohol Dependence 2019;202:149–55.31351341
Audrain-McGovern J, Strasser AA, Wileyto EP. The impact of flavoring on the rewarding and reinforcing value of e-cigarettes with nicotine among young adult smokers. Drug and Alcohol Dependence 2016;166:263–7.27426010
Azagba S, Latham K, Shan L. Exposure to secondhand smoke in vehicles among Canadian adolescents: years after the adoption of smoke-free car laws. Addictive Behavior Reports 2019;10:100215.
Babb S, Malarcher A, Asman K, Johns M, Caraballo R, VanFrank B, Garrett B. Disparities in cessation behaviors between Hispanic and non-Hispanic White adult cigarette smokers in the United States, 2000–2015. Preventing Chronic Disease 2020;17:E10.31999539
Babb S, Malarcher A, Schauer G, Asman K, Jamal A. Quitting smoking among adults—United States, 2000–2015. Morbidity and Mortality Weekly Report 2017;65:1457–64.28056007
Babb S, McNeil C, Kruger J, Tynan MA. Secondhand smoke and smoking restrictions in casinos: a review of the evidence. Tobacco Control 2015;24(1):11–7.24610051
Baig SA, Pepper JK, Morgan JC, Brewer NT. Social identity and support for counteracting tobacco company marketing that targets vulnerable populations. Social Science & Medicine 2017;182:136–41.28427731
Bailey SR, Heintzman J, Jacob RL, Puro J, Marino M. Disparities in smoking cessation assistance in U.S. primary care clinics. American Journal of Public Health 2018;108(8):1082–90.29927641
Bailey SR, Marino M, Ezekiel-Herrera D, Schmidt T, Angier H, Hoopes MJ, DeVoe JE, Heintzman J, Huguet N. Tobacco cessation in Affordable Care Act Medicaid expansion states versus non-expansion states. Nicotine & Tobacco Research 2020;22(6):1016–22.31123754
Baker TB, Berg KM, Adsit RT, Skora AD, Swedlund MP, Zehner ME, McCarthy DE, Glasgow RE, Fiore MC. Closed-loop electronic referral from primary care clinics to a state tobacco cessation quitline: effects using real-world implementation training. American Journal of Preventive Medicine 2021;60(3 Suppl 2):S113–S122.33663698
Bala MM, Strzeszynski L, Topor-Madry R. Mass media interventions for smoking cessation in adults. Cochrane Database of Systematic Reviews 2017, Issue 11. Art. No.: CD004704. DOI: 10.1002/14651858.CD004704.pub4.
Bala MM, Strzeszynski L, Topor-Madry R, Cahill K. Mass media interventions for smoking cessation in adults. Cochrane Database of Systematic Reviews 2013, Issue 6. Art. No.: CD004704. DOI: 10.1002/14651858.CD004704.pub3.
Balbach ED, Barbeau EM, Manteufel V, Pan J. Political coalitions for mutual advantage: the case of the Tobacco Institute’s Labor Management Committee. American Journal of Public Health 2005;95(6):985–93.15914820
Ballbè M, Martínez-Sánchez JM, Sureda X, Fu M, Pérez-Ortuño R, Pascual JA, Saltó E, Fernández E. Cigarettes vs. e-cigarettes: passive exposure at home measured by means of airborne marker and biomarkers. Environmental Research 2014;135:76–80.25262078
Bandura A. Social cognitive theory: an agentic perspective. Annual Review of Psychology 2001;52:1–26.
Barbeau E, Li Y, Calderon P, Hartman C, Quinn M, Markennen P, Roelofs C, Frazier L, Levenstein C. Results of a union-based smoking cessation intervention for apprentice iron workers. Cancer Causes and Control 2006;17:53–61.16411053
Barbeau E, Li Y, Sorensen G, Conlan K, Youngstrom R, Emmons K. Coverage of smoking cessation treatment by union health and welfare funds. American Journal of Public Health 2001a;91(9):1412–4.11527772
Barbeau E, McLellan D, Levenstein C, Delaurier G, Kelder G, Sorensen G. Reducing occupation-based disparities related to tobacco: roles for occupational health and organized labor. American Journal of Industrial Medicine 2004;46(2):170–9.15273970
Barbeau E, Yaus K, McLellan D, Levenstein C, Youngstrom R, Siqueira CE, Sorensen G. Organized labor, public health, and tobacco control policy: a dialogue toward action, Conference report and joint recommendations for Action. New Solutions 2001b;11(2):121–39.17208904
Barbeau EM, Delaurier G, Kelder G, McLellan D, Sorensen G, Balbach ED, Levenstein C. A decade of work on organized labor and tobacco control: reflections on research and coalition building in the United States. Journal of Public Health Policy 2007;28(1):118–35.17363942
Barbeau EM, Kelder G, Ahmed S, Mantuefel V, Balbach ED. From strange bedfellows to natural allies: the shifting allegiance of fire service organisations in the push for federal fire-safe cigarette legislation. Tobacco Control 2005;14(5):338–45.16183985
Bardus M, El Boukhari N, Nakkash R. Development and evaluation of smoke-free or tobacco-free policies in university settings: a systematic scoping review. Health Education Research 2020;35(4):306–51.32702134
Barker DC, Schleicher NC, Ababseh K, Johnson TO, Henriksen L. ENDS retailers and marketing near university campuses with and without tobacco-free policies. Tobacco Induced Diseases 2018;16:47.30687532
Baron SL, Beard S, Davis LK, Delp L, Forst L, Kidd-Taylor A, Liebman AK, Linnan L, Punnett L, Welch LS. Promoting integrated approaches to reducing health inequities among low-income workers: applying a social ecological framework. American Journal of Industrial Medicine 2014;57(5):539–56.23532780
Bartosch WJ, Pope GC. Local restaurant smoking policy enactment in Massachusetts. Journal of Public Health Management and Practice 1999;5(1):63–73.
Baskerville NB, Dash D, Shuh A, Wong K, Abramowicz A, Yessis J, Kennedy RD. Tobacco use cessation interventions for lesbian, gay, bisexual, transgender and queer youth and young adults: a scoping review. Preventive Medicine Reports 2017;6:53–62.28271021
Baskerville NB, Hayward L, Brown KS, Hammond D, Kennedy RD, Campbell HS. Impact of Canadian tobacco packaging policy on quitline reach and reach equity. Preventive Medicine 2015a;81:243–50.26400639
Baskerville NB, Struik LL, Hammond D, Guindon GE, Norman CD, Whittaker R, Burns CM, Grindrod KA, Brown KS. Effect of a mobile phone intervention on quitting smoking in a young adult population of smokers: randomized controlled trial study protocol. JMIR Research Protocols 2015b;4(1):e10.25599695
Bayly J, Trad C, Saint-Fort L, Andrews M, Patel M, Haynie D, Simons-Morton B, Choi K. Adoption of electronic-cigarette-free, hookah-free and American College Health Association recommended tobacco-free policies among a national sample of postsecondary educational institutions. Journal of American College Health 2020;68(1):26–31.30388931
Been JV, Millett C, Lee JT, van Schayck CP, Sheikh A. Smoke-free legislation and childhood hospitalisations for respiratory tract infections. European Respiratory Journal 2015;46(3):697–706.26022951
Behbod B, Sharma M, Baxi R, Roseby R, Webster P. Family and career smoking control programmes for reducing children’s exposure to environmental tobacco smoke. Cochrane Database of Systematic Reviews 2018, Issue 1. Art. No.: CD001746. DOI: 10.1002/14651858.CD001746.pub4.
Benders J, Bleijerveld H, Schouteten R. Continuous improvement, burnout and job engagement: a study in a Dutch nursing department. International Journal of Health Planning and Management 2017;32(4):481–91.27230487
Bennett BL, Deiner M, Pokhrel P. College anti-smoking policies and student smoking behavior: a review of the literature. Tobacco Induced Diseases 2017;15(1):11.28163669
Benowitz NL, Dains KM, Dempsey D, Wilson M, Jacob P. Racial differences in the relationship between number of cigarettes smoked and nicotine and carcinogen exposure. Nicotine & Tobacco Research 2011;13(9):772–83.21546441
Benowitz NL, Nardone N, Dains KM, Hall SM, Stewart S, Dempsey D, Jacob P 3rd. Effect of reducing the nicotine content of cigarettes on cigarette smoking behavior and tobacco smoke toxicant exposure: 2-year follow up. Addiction 2015;110(10):1667–75.26198394
Berg CJ, Abroms LC, Levine H, Romm KF, Khayat A, Wysota CN, Duan Z, Bar-Zeev Y. IQOS marketing in the U.S.: the need to study the impact of FDA modified exposure authorization, marketing distribution channels, and potential targeting of consumers. International Journal of Environmental Research and Public Health 2021a;18(19):10551.34639851
Berg CJ, An LC, Thomas JL, Lust K, Sanem JR, Swan DW, Ahluwalia JS. Differences in smoking patterns, attitudes, and motives among two-year college and four-year university students. Health Education Research 2011;26(4):614–23.21447751
Berg CJ, Romm KF, Bar-Zeev Y, Abroms LC, Klinkhammer K, Wysota CN, Khayat A, Broniatowski DA, Levine H. IQOS marketing strategies in the USA before and after U.S. FDA modified risk tobacco product authorisation. Tobacco Control 2021b.
Berg CJ, Schleicher NC, Johnson TO, Barker DC, Getachew B, Weber A, Park AJ, Patterson A, Dorvil S, Fairman RT, . Vape shop identification, density and place characteristics in six metropolitan areas across the U.S. Preventive Medicine Reports 2020;19:101137.32566458
Berg CJ, Yang YT, Pratt-Chapman ML, Douglas Evans W, Cupertino A-P, Horn K, Bernat DH, Abroms LC, Tercyak KP. Campus tobacco control policies and cessation interventions in college students: a commentary calling for research and action to address tobacco-related health disparities. Translational Behavioral Medicine 2021c;11(4):1030–6.32893870
Berger I, Mooney-Somers J. Smoking cessation programs for lesbian, gay, bisexual, transgender, and intersex people: a content-based systematic review. Nicotine & Tobacco Research 2017;19(12):1408–17.27613909
Bernstein SL, Boudreaux ED, Cydulka RK, Rhodes KV, Lettman NA, Almeida S-L, McCullough LB, Mizouni S, Kellermann AL. Tobacco control interventions in the emergency department: a joint statement of emergency medicine organizations. Annals of Emergency Medicine 2006;48(4):e417–e426.16997678
Bernstein SL, D’Onofrio G, Rosner J, O’Malley S, Makuch R, Busch S, Pantalon MV, Toll B. Successful tobacco dependence treatment in low-income emergency department patients: a randomized trial. Annals of Emergency Medicine 2015;66(2):140–7.25920384
Bernstein SL, Rosner J, DeWitt M, Tetrault J, Hsiao AL, Dziura J, Sussman S, O’Connor P, Toll B. Design and implementation of decision support for tobacco dependence treatment in an inpatient electronic medical record: a randomized trial. Translational Behavioral Medicine 2017;7(2):185–95.28194729
Bernstein SL, Weiss J-M, Toll B, Zbikowski SM. Association between utilization of quitline services and probability of tobacco abstinence in low-income smokers. Journal of Substance Abuse Treatment 2016;71:58–62.27776679
Bertera RL. The effects of workplace health promotion on absenteeism and employment costs in a large industrial population. American Journal of Public Health 1990;80(9):1101–5.2382748
Bertera RL. Behavioral risk factor and illness day changes with workplace health promotion: two-year results. American Journal of Health Promotion 1993;7(5):365–73.10148712
Blackman KCA, Smiley SL, Kintz NM, Rodriguez YL, Bluthenthal RN, Chou C-P, Cruz TB, Barahona R, Pentz MA, Samet JM, . Retailers’ perceptions of FDA tobacco regulation authority. Tobacco Regulatory Science 2019;5(3):291–300.32864396
Blake KD, Klein AL, Walpert L, Casey L, Hallett C, Douglas C, Sinha B, Koh HK. Smoke-free and tobacco-free colleges and universities in the United States. Tobacco Control 2020;29(3):289–94.31266902
Blakely T, Gartner C. Tobacco taxes have mixed effects on socioeconomic disparities. Lancet Public Health 2019;4(12):e595–e596.31759896
Blanchard JW, Petherick JT, Basara H. Stakeholder engagement: a model for tobacco policy planning in Oklahoma Tribal communities. American Journal of Preventive Medicine 2015;48(1 Suppl 1):S44–S46.25528706
Boakye E, Osuji N, Erhabor J, Obisesan O, Osei AD, Mirbolouk M, Stokes AC, Dzaye O, El Shahawy O, Hirsch GA, . Assessment of patterns in e-cigarette use among adults in the U.S., 2017–2020. JAMA Network Open 2022;5(7):e2223266.35867060
Bock BC, Papandonatos GD, de Dios MA, Abrams DB, Azam MM, Fagan M, Sweeney PJ, Stein MD, Niaura R. Tobacco cessation among low-income smokers: motivational enhancement and nicotine patch treatment. Nicotine & Tobacco Research 2014;16(4):413–22.24174612
Bold KW, Jatlow P, Fucito LM, Eid T, Krishnan-Sarin S, O’Malley S. Evaluating the effect of switching to nonmenthol cigarettes among current menthol smokers: an empirical study of a potential ban of characterising menthol flavour in cigarettes. Tobacco Control 2020;29(6):624–30.31685586
Bonell C, Dickson K, Hinds K, Melendez-Torres G, Stansfield C, Fletcher A, Thomas J, Lester K, Oliver E, Murphy S. The effects of positive youth development interventions on substance use, violence and inequalities: systematic review of theories of change, processes and outcomes. Public Health Research 2016;4(5).
Borland R, Yong HH, Cummings KM, Hyland A, Anderson S, Fong GT. Determinants and consequences of smoke-free homes: findings from the International Tobacco Control (ITC) Four Country Survey. Tobacco Control 2006;15(Suppl 3):iii42–iii50.16754946
Borrelli B, McQuaid EL, Novak SP, Hammond SK, Becker B. Motivating Latino caregivers of children with asthma to quit smoking: a randomized trial. Journal of Consulting and Clinical Psychology 2010;78(1):34–43.20099948
Bourke J, Brooks MM, Siegel SD. Policy recommendations for reducing tobacco exposure for youth and adults in Wilmington, Delaware. Delaware Journal of Public Health 2022;8(3):20–3.
Bourne DE, Williams R, Osbahr L, Roemhildt M, Villanti AC. Implementation of Quitline Financial Incentives to Increase Counseling Sessions Among Adults Who Use Menthol Tobacco Products. Health Promotion Practice 2023:15248399231171143.
Boyle R, Solberg L, Fiore M. Use of electronic health records to support smoking cessation. Cochrane Database of Systematic Reviews 2014, Issue 12. Art. No.: CD008743. DOI: 10.1002/14651858.CD008743.pub3.
Boyle RG, Stanton CA, Sharma E, Tang Z. Examining quit attempts and successful quitting after recent cigarette tax increases. Preventive Medicine 2019;118:226–31.30408448
Braverman MT, Geldhof GJ, Hoogesteger LA, Johnson JA. Predicting students’ noncompliance with a smokefree university campus policy. Preventive Medicine 2018;114:209–16.30049663
Breen RJ, Ferguson SG, Palmer MA. Higher incentive amounts do not appear to be associated with greater quit rates in financial incentive programmes for smoking cessation. Addictive Behaviors 2020;110:106513.32590220
Brennan E, Gibson LA, Kybert-Momjian A, Liu J, Hornik RC. Promising themes for antismoking campaigns targeting youth and young adults. Tobacco Regulatory Science 2017;3(1):29–46.28989949
Bresnahan MP, Sacks R, Farley SM, Mandel-Ricci J, Patterson T, Lamberson P. Going tobacco-free on 24 New York City university campuses: a public health agency’s partnership with a large urban public university system. Journal of American College Health 2016;64(4):343–7.26700322
Briggs R. New PA budget strips Philadelphia of power to regulate cigarette sales, June 26, 2018; <https://www.cityandstatepa.com/politics/2018/06/new-pa-budget-strips-philadelphia-power-regulate-cigarette-sales/364680/>; accessed: February 26, 2024.
Brody AL, Mukhin AG, La Charite J, Ta K, Farahi J, Sugar CA, Mamoun MS, Vellios E, Archie M, Kozman M, . Up-regulation of nicotinic acetylcholine receptors in menthol cigarette smokers. International Journal of Neuropsychopharmacology 2013;16(5):957–66.23171716
Brody DJ, Faust E, Tsai J. Secondhand smoke exposure among nonsmoking adults: United States, 2015–2018. NCHS Data Brief 2021;(369):1–8.
Brokenleg IS, Barber TK, Bennett NL, Peart Boyce S, Blue Bird Jernigan V. Gambling with our health: smoke-free policy would not reduce tribal casino patronage. American Journal of Preventive Medicine 2014;47(3):290–9.24951040
Brouwer AF, Jeon J, Cook SF, Usidame B, Hirschtick JL, Jimenez-Mendoza E, Mistry R, Fleischer NL, Holford TR, Mendez D, . The impact of menthol cigarette flavor in the U.S.: cigarette and ENDS transitions by sociodemographic group. American Journal of Preventive Medicine 2022;62(2):243–51.34740512
Brown-Johnson CG, Cataldo JK, Orozco N, Lisha NE, Hickman NJ 3rd, Prochaska JJ. Validity and reliability of the Internalized Stigma of Smoking Inventory: an exploration of shame, isolation, and discrimination in smokers with mental health diagnoses. American Journal on Addictions 2015;24(5):410–8.25930661
Brown T, Platt S, Amos A. Equity impact of population-level interventions and policies to reduce smoking in adults: a systematic review. Drug and Alcohol Dependence 2014;138:7–16.24674707
Brownson RC, Hopkins DP, Wakefield MA. Effects of smoking restrictions in the workplace. Annual Review of Public Health 2002;23:333–48.
Bryant J, Bonevski B, Paul C, McElduff P, Attia J. A systematic review and meta-analysis of the effectiveness of behavioural smoking cessation interventions in selected disadvantaged groups. Addiction 2011;106(9):1568–85.21489007
Bundy LT, Haardorfer R, Kegler MC, Owolabi S, Berg CJ, Escoffery C, Thompson T, Mullen PD, Williams R, Hovell M, . Disseminating a smokefree homes program to low socioeconomic status households in the United States through 2-1-1: results of a national impact evaluation. Nicotine & Tobacco Research 2020;22(4):498–505.30517679
Burcu M, Steinberger EK, Sorkin JD. Health care access and smoking cessation among cancer survivors: implications for the Affordable Care Act and survivorship care. Journal of Cancer Survivorship 2016;10(1):1–10.25862543
Burgess DJ, van Ryn M, Noorbaloochi S, Clothier B, Taylor BC, Sherman S, Joseph AM, Fu SS. Smoking cessation among African American and White smokers in the Veterans Affairs health care system. American Journal of Public Health 2014;104(Suppl 4):S580–S587.25100424
Burns EK, Deaton EA, Levinson AH. Rates and reasons: disparities in low intentions to use a state smoking cessation quitline. American Journal of Health Promotion 2011;25(5 Suppl):S59–S65.21510788
Burns EK, Levinson AH. Reaching Spanish-speaking smokers: state-level evidence of untapped potential for QuitLine utilization. American Journal of Public Health 2010;100(Suppl 1):S165–S710.20147692
Burris S, Berman ML, Penn M, Holiday TR. The New Public Health Law: A Transdisciplinary Approach to Practice and Advocacy. New York (NY): Oxford University Press, 2018.
Byaruhanga J, Paul CL, Wiggers J, Byrnes E, Mitchell A, Lecathelinais C, Bowman J, Campbell E, Gillham K, Tzelepis F. The short-term effectiveness of real-time video counselling on smoking cessation among residents in rural and remote areas: an interim analysis of a randomised trial. Journal of Substance Abuse Treatment 2021;131:108448.34098302
Byron MJ, Jeong M, Abrams DB, Brewer NT. Public misperception that very low nicotine cigarettes are less carcinogenic. Tobacco Control 2018;27(6):712–4.29363610
Cabriales JA, Cooper TV, Salgado-Garcia F, Naylor N, Gonzalez Jr E. A randomized trial of a brief smoking cessation intervention in a light and intermittent Hispanic sample. Experimental and Clinical Psychopharmacology 2012;20(5):410–9.22731733
Cadham CJ, Sanchez-Romero LM, Fleischer NL, Mistry R, Hirschtick JL, Meza R, Levy DT. The actual and anticipated effects of a menthol cigarette ban: a scoping review. BMC Public Health 2020;20(1):1055.32641026
Cahill K, Lancaster T. Workplace interventions for smoking cessation. Cochrane Database of Systematic Reviews 2014, Issue 2. Art. No.: CD003440. DOI: 10.1002/14651858.CD003440.pub4.
Cahill SR, Baker K, Deutsch MB, Keatley J, Makadon HJ. Inclusion of sexual orientation and gender identity in stage 3 meaningful use guidelines: a huge step forward for LGBT health. LGBT Health 2016;3(2):100–2.26698386
Calhoun PS, Wilson SM, Hicks TA, Thomas SP, Dedert EA, Hair LP, Bastian LA, Beckham JC. Racial and sociodemographic disparities in internet access and ehealth intervention utilization among veteran smokers. Journal of Racial and Ethnic Health Disparities 2016.
California Department of Education. Request for applications: youth engagement to address tobacco-related disparities, n.d.; <https://www.cde.ca.gov/fg/fo/profile.asp?id=5663>; accessed: June 16, 2023.
California Department of Public Health. Matrix of Local Ordinances Restricting Tobacco Retailers Near Schools. Sacramento (CA): American Lung Association in California, The Center for Tobacco Policy & Organizing, 2016.
Campaign for Tobacco-Free Kids. Heated Tobacco Products: Global Regulation, 2020; <https://www.tobaccofreekids.org/assets/global/pdfs/en/HTP_regulation_en.pdf>; accessed: July 10, 2022.
Campaign for Tobacco-Free Kids. States & Localities That Have Restricted The Sale Of Flavored Tobacco Products, June 16, 2022; <https://www.tobaccofreekids.org/assets/factsheets/0398.pdf>; accessed: February 14, 2023.
Campaign for Tobacco-Free Kids. Flavored Tobacco Sales Restrictions: Promising Evidence for Reducing Youth Access and Tobacco Use, January 31, 2024a; <https://www.tobaccofreekids.org/assets/factsheets/0409.pdf>; accessed: February 26, 2024.
Campaign for Tobacco-Free Kids. States & Localities That Have Restricted The Sale Of Flavored Tobacco Products, February 14, 2024b; <https://www.tobaccofreekids.org/assets/factsheets/0398.pdf>; accessed: February 14, 2024.
Cannonier C, Burke MG, Steward K. Smoking, health and academic outcomes: evidence from a limited smoking campus policy. Health Economics, Policy and Law 2019;14(2):205–30.29925453
Cantrell J, Vallone DM, Thrasher JF, Nagler RH, Feirman SP, Muenz LR, He DY, Viswanath K. Impact of tobacco-related health warning labels across socioeconomic, race and ethnic groups: results from a randomized web-based experiment. PLoS One 2013;8(1):e52206.23341895
Cao S, Yang C, Gan Y, Lu Z. The health effects of passive smoking: an overview of systematic reviews based on observational epidemiological evidence. PLoS One 2015;10(10):e0139907.26440943
Carnethon M, Whitsel LP, Franklin BA, Kris-Etherton P, Milani R, Pratt CA, Wagner GR. Worksite wellness programs for cardiovascular disease prevention: a policy statement from the American Heart Association. Circulation 2009;120(17):1725–41.19794121
Carr D, Adler S, Winig BD, Montez JK. Equity first: conceptualizing a normative framework to assess the role of preemption in public health. Milbank Quarterly 2020;98(1):131–49.31951048
Carrillo S, Nazir N, Howser E, Shenkman L, Laxson M, Scheuermann TS, Richter KP. Impact of the 2015 CMS inpatient psychiatric facility quality reporting rule on tobacco treatment. Nicotine & Tobacco Research 2017;19(8):976–82.28013270
Carroll DM, Lindgren BR, Dermody SS, Denlinger-Apte R, Egbert A, Cassidy RN, Smith TT, Pacek LR, Allen AM, Tidey JW, . Impact of nicotine reduction in cigarettes on smoking behavior and exposure: are there differences by race/ethnicity, educational attainment, or gender? Drug and Alcohol Dependence 2021;225:108756.34051544
Carter BL, Lam CY, Robinson JD, Paris MM, Waters AJ, Wetter DW, Cinciripini PM. Generalized craving, self-report of arousal, and cue reactivity after brief abstinence. Nicotine & Tobacco Research 2009;11(7):823–6.19477914
Casseus M, Graber JM, West B, Wackowski O. Tobacco use disparities and disability among U.S. college students. Journal of American College Health 2020:1–6.
Cassidy RN, Colby SM, Tidey JW, Jackson KM, Cioe PA, Krishnan-Sarin S, Hatsukami D. Adolescent smokers’ response to reducing the nicotine content of cigarettes: acute effects on withdrawal symptoms and subjective evaluations. Drug and Alcohol Dependence 2018;188:153–60.29775959
Castellan RM, Chosewood LC, Trout D, Wagner GR, Caruso CC, Mazurek J, McCrone SH, Weissman DN. Promoting Health and Preventing Disease and Injury through Workplace Tobacco Policies. Current Intelligence Bulletin 67, 2015; <https://www.cdc.gov/niosh/docs/2015-113/pdfs/FY15_CIB-67_2015-113_v3.pdf?id=10.26616/NIOSHPUB2015113>; accessed: April 16, 2020.
Castro Y, Fernandez ME, Strong LL, Stewart DW, Krasny S, Hernandez Robles E, Heredia N, Spears CA, Correa-Fernandez V, Eakin E, . Adaptation of a counseling intervention to address multiple cancer risk factors among overweight/obese Latino smokers. Health Education & Behavior 2015;42(1):65–72.25527143
Catalano RF, Berglund ML, Ryan JA, Lonczak HS, Hawkins JD. Positive youth development in the United States: Research findings on evaluations of positive youth development programs. The Annals of the American Academy of Political and Social Science 2004;591(1):98–124.
Cataldo JK, Hunter M, Petersen AB, Sheon N. Positive and instructive anti-smoking messages speak to older smokers: a focus group study. Tobacco Induced Diseases 2015;13(1):2.25653578
Center for Behavioral Health Statistics and Quality. Results from the 2019 National Survey on Drug Use and Health: detailed tables—table 8.44B. Rockville (MD): Substance Abuse and Mental Health Services Administration, 2020; <https://www.samhsa.gov/data/sites/default/files/reports/rpt29394/NSDUHDetailedTabs2019/NSDUHDetTabsSect8pe2019.htm?s=8.44&#tab8-44b>; accessed: July 12, 2022.
Centers for Disease and Control Prevention. Schools Supporting Students to Quit Tobacco Use as an Alternative to Suspension: Lessons from the Field, n.d.; <https://www.cdc.gov/tobacco/basic_information/e-cigarettes/pdfs/Supporting-Schools-to-Quit-Tobacco-Use-as-an-Alternative-to-Suspension.pdf>; accessed: July 10, 2023.
Centers for Disease Control and Prevention. Response to increases in cigarette prices by race/ethnicity, income, and age groups—United States, 1976–1993. Morbidity and Mortality Weekly Report 1998;47(29):605–9.9699809
Centers for Disease Control and Prevention. Preemptive state tobacco-control laws—United States, 1982–1998. Morbidity and Mortality Weekly Report 1999;(51):1112–14.9921728
Centers for Disease Control and Prevention. Designing and Implementing an Effective Tobacco Counter-Marketing Campaign. (1st ed.). Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, October 2003.
Centers for Disease Control and Prevention. Vital signs: nonsmokers’ exposure to secondhand smoke—United States, 1999–2008. Morbidity and Mortality Weekly Report 2010;59(35):1141–6.20829748
Centers for Disease Control and Prevention. State preemption of local tobacco control policies restricting smoking, advertising, and youth access—United States, 2000–2010. Morbidity and Mortality Weekly Report 2011a;60(33):1124–7.21866085
Centers for Disease Control and Prevention. State smokefree laws for worksites, restaurants, and bars—United States, 2000–2010. Morbidity and Mortality Weekly Report 2011b;60(15):472–5.21508923
Centers for Disease Control and Prevention. Comprehensive smoke-free laws—50 largest U.S. cities, 2000 and 2012. Morbidity and Mortality Weekly Report 2012a;61(45):914–7.23151950
Centers for Disease Control and Prevention. Comprehensive smoke-free laws—50 largest U.S. cities, 2000 and 2012. Morbidity and Mortality Weekly Report 2012b;61(45):914–7.23151950
Centers for Disease Control and Prevention. The Guide to Community Preventive Services, 2012c; <http://www.thecommunityguide.org/index.html>; accessed: April 16, 2020.
Centers for Disease Control and Prevention. Increases in quitline calls and smoking cessation website visitors during a national tobacco education campaign—March 19–June 10, 2012. Morbidity and Mortality Weekly Report 2012d;61(34):667–70.22932300
Centers for Disease Control and Prevention. Impact of a national tobacco education campaign on weekly numbers of quitline calls and website visitors—United States, March 4–June 23, 2013. Morbidity and Mortality Weekly Report 2013;62(37):763–7.24048152
Centers for Disease Control and Prevention. Best Practices for Comprehensive Tobacco Control Programs—2014. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2014; <https://www.cdc.gov/tobacco/stateandcommunity/guides/pdfs/2014/comprehensive.pdf>; accessed: November 23, 2023.
Centers for Disease Control and Prevention. Best Practices User Guide: Health Equity in Tobacco Prevention and Control. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2015.
Centers for Disease Control and Prevention. Best Practices User Guide: Cessation in Tobacco Prevention and Control, 2020; <https://www.cdc.gov/tobacco/stateandcommunity/guides/pdfs/best-practices-cessation-user-guide-508.pdf>;>; accessed: June 19, 2023.
Centers for Disease Control and Prevention. STATE System preemption fact sheet, August 5, 2022; <https://www.cdc.gov/statesystem/factsheets/preemption/Preemption.html>; accessed: September 12, 2022.
Centers for Disease Control and Prevention. QuickStats: Percentage distribution of cigarette smoking status among current adult e-cigarette users, by age group—National Health Interview Survey, United States, 2021. Morbidity and Mortality Weekly Report 2023;72(10):270.36893067
Centers for Disease Control and Prevention. About social determinants of health, n.d.a; <https://www.cdc.gov/socialdeterminants/about.htm>; accessed: June 24, 2022.
Centers for Disease Control and Prevention. About underlying cause of death, 1999–2019, n.d.b; <http://wonder.cdc.gov/ucd-icd10.html>; accessed: October 12, 2021.
Centers for Disease Control and Prevention. Economic trends in tobacco, n.d.c; <https://www.cdc.gov/tobacco/data_statistics/fact_sheets/economics/econ_facts/index.htm>; accessed: July 30, 2022.
Centers for Disease Control and Prevention. Heart health, n.d.d; <https://www.cdc.gov/marijuana/health-effects/heart-health.html>; accessed: July 9, 2022.
Centers for Disease Control and Prevention. Real stories, n.d.e; <https://www.cdc.gov/tobacco/campaign/tips/stories/index.html>; accessed: July 29, 2022.
Centers for Disease Control and Prevention. Secondhand marijuana smoke, n.d.f; <https://www.cdc.gov/marijuana/health-effects/second-hand-smoke.html>; accessed: July 9, 2022.
Centers for Disease Control and Prevention. State Activities Tracking and Evaluation (STATE) System, n.d.g; <https://www.cdc.gov/statesystem/index.html>; accessed: May 30, 2019.
Centers for Disease Control and Prevention. STATE System e-cigarette fact sheet, n.d.h; <https://www.cdc.gov/statesystem/factsheets/ecigarette/ECigarette.html>; accessed: July 9, 2022.
Centers for Disease Control and Prevention. STATE System smokefree indoor air fact sheet, n.d.i; <https://www.cdc.gov/statesystem/factsheets/sfia/SmokeFreeIndoorAir.html>; accessed: July 9, 2022.
Centers for Disease Control and Prevention. STATE System vehicles fact sheet, n.d.j; <https://www.cdc.gov/statesystem/factsheets/vehicles/Vehicles.html>; accessed: June 20, 2023.
Centers for Disease Control and Prevention. Tobacco industry marketing, n.d.k; <https://www.cdc.gov/tobacco/data_statistics/fact_sheets/tobacco_industry/marketing/index.htm>; accessed: July 12, 2022.
Centers for Medicare & Medicaid Services. Medicare and Medicaid programs; electronic health record incentive program; Final Rule. Federal Register 2010;75(144):44314–588.
Centers for Medicare & Medicaid Services. Medicare issues payment updates and policy changes for inpatient psychiatric facilities, 2014; <https://www.cms.gov/newsroom/fact-sheets/medicare-issues-payment-upades-and-policy-changes-inpatient-psychiatric-facilities>; accessed: April 16, 2020.
Centers for Medicare & Medicaid Services. Medicaid Incentives for Prevention of Chronic Diseases: Final Evaluation Report, April 2017; <https://downloads.cms.gov/files/cmmi/mipcd-finalevalrpt.pdf>; accessed: June 28, 2023.
Centers for Medicare & Medicaid Services. Medicare program; FY 2019 Inpatient Psychiatric Facilities Prospective Payment System and Quality Reporting Updates for Fiscal Year Beginning October 1, 2018 (FY 2019). Federal Register 2018;83(89):21104–38.
Centers for Medicare & Medicaid Services. Medicare Shared Savings Program: about the program, 2020; <https://www.cms.gov/Medicare/Medicare-Fee-for-Service-Payment/sharedsavingsprogram/about>; accessed: April 22, 2020.
Centers for Medicare & Medicaid Services. Hospital general information, April 11, 2023; <https://data.cms.gov/provider-data/dataset/xubh-q36u>; accessed: June 27, 2023.
Chaiton M, Mecredy G, Rehm J, Samokhvalov AV. Tobacco retail availability and smoking behaviours among patients seeking treatment at a nicotine dependence treatment clinic. Tobacco Induced Diseases 2014;12(1):19.25745380
Chaiton M, Papadhima I, Schwartz R, Cohen JE, Soule EK, Zhang B, Eissenberg T. Product substitution after a real-world menthol ban: a cohort study. Tobacco Regulatory Science 2020a;6(3):205–12.34350312
Chaiton M, Schwartz R, Cohen JE, Soule E, Eissenberg T. Association of Ontario’s ban on menthol cigarettes with smoking behavior 1 month after implementation. JAMA Internal Medicine 2018;178(5):710–1.29507934
Chaiton M, Schwartz R, Cohen JE, Soule E, Zhang B, Eissenberg T. Prior daily menthol smokers more likely to quit 2 years after a menthol ban than non-menthol smokers: a population cohort study. Nicotine & Tobacco Research 2021a;23(9):1584–9.33693745
Chaiton M, Schwartz R, Kundu A, Houston C, Nugent R. Analysis of wholesale cigarette sales in Canada after menthol cigarette bans. JAMA Network Open 2021b;4(11):e2133673.34751762
Chaiton M, Schwartz R, Shuldiner J, Tremblay G, Nugent R. Evaluating a real world ban on menthol cigarettes: an interrupted time-series analysis of sales. Nicotine & Tobacco Research 2020b;22(4):576–9.30887032
Chaiton MO, Cunningham R, Hagen L, Dubray J, Borland T. Taking global leadership in banning menthol and other flavours in tobacco: Canada’s experience. Tobacco Control 2022;31(2):202–11.35241589
Chaiton MO, Nicolau I, Schwartz R, Cohen JE, Soule E, Zhang B, Eissenberg T. Ban on menthol-flavoured tobacco products predicts cigarette cessation at 1 year: a population cohort study. Tobacco Control 2020c;29(3):341–7.31147474
Chaiton MO, Schwartz R, Tremblay G, Nugent R. Association of flavoured cigar regulations with wholesale tobacco volumes in Canada: an interrupted time series analysis. Tobacco Control 2019;28(4):457–61.30135113
Chaloupka F. Rational addictive behavior and cigarette-smoking. Journal of Political Economy 1991;99(4):722–42.
Chaloupka FJ. Macro-social influences: the effects of prices and tobacco-control policies on the demand for tobacco products. Nicotine & Tobacco Research 1999;1(Suppl 1):S105–S109.11072413
Chaloupka FJ, Pacula RL. Sex and race differences in young people’s responsiveness to price and tobacco control policies. Tobacco Control 1999;8(4):373–7.10629242
Chaloupka FJ, Straif K, Leon ME. Effectiveness of tax and price policies in tobacco control. Tobacco Control 2011;20(3):235–8.21115556
Chaloupka FJ, Tauras JA. Taxation of Emerging Tobacco Products. Chicago (IL): Tobacconomics, 2020.
Chaloupka FJ, Yurekli A, Fong GT. Tobacco taxes as a tobacco control strategy. Tobacco Control 2012;21(2):172–80.22345242
Chan L, O’Hara B, Phongsavan P, Bauman A, Freeman B. Review of evaluation metrics used in digital and traditional tobacco control campaigns. Journal of Medical Internet Research 2020;22(8):e17432.32348272
ChangeLab Solutions. Equitable Enforcement to Achieve Health Equity: An Introductory Guide for Policymakers and Practitioners, 2020; <https://www.changelabsolutions.org/product/equitable-enforcement-achieve-health-equity>; accessed: June 16, 3023.
Chapman S. Curbing the epidemic: governments and the economics of tobacco control. BMJ 2000;320(7228):192.10634758
Chen-Sankey J, Bover-Manderski MT. Importance of a balanced public health approach when assessing recent patterns in the prevalence of adult e-cigarette use in the U.S. JAMA Network Open 2022;5(7):e2223274.35867066
Chen-Sankey JC, Mead-Morse EL, Le D, Rose SW, Quisenberry AJ, Delnevo CD, Choi K. Cigar-smoking patterns by race/ethnicity and cigar type: a nationally representative survey among U.S. adults. American Journal of Preventive Medicine 2021;60(1):87–94.33341182
Chen C, Anderson CM, Babb SD, Frank R, Wong S, Kuiper NM, Zhu S-H. Evaluation of the Asian Smokers’ Quitline: a centralized service for a dispersed population. American Journal of Preventive Medicine 2021;60(3 Suppl 2):S154–S162.33663703
Chen C, Huang YB, Liu XO, Gao Y, Dai HJ, Song FJ, Li WQ, Wang J, Yan Y, Wang PS, . Active and passive smoking with breast cancer risk for Chinese females: a systematic review and meta-analysis. Chinese Journal of Cancer 2014;33(6):306–16.24823992
Chen L-S, Baker TB, Miller JP, Bray M, Smock N, Chen J, Stoneking F, Culverhouse RC, Saccone NL, Amos CI, . Genetic variant in CHRNA5 and response to varenicline and combination nicotine replacement in a randomized placebo-controlled trial. Clinical Pharmacology and Therapeutics 2020;108(6):1315–25.32602170
Cheng KW, Glantz SA, Lightwood JM. Association between smokefree laws and voluntary smokefreehome rules. American Journal of Preventive Medicine 2011;41(6):566–72.22099232
Cheng KW, Okechukwu CA, McMillen R, Glantz SA. Association between clean indoor air laws and voluntary smokefree rules in homes and cars. Tobacco Control 2015;24(2):168–74.24114562
Cherniack M. Integrated health programs, health outcomes, and return on investment: measuring workplace health promotion and integrated program effectiveness. Journal of Occupational and Environmental Medicine 2013;55(12 Suppl):S38–S45.24284755
Cherrington A, Williams JH, Foster PP, Coley HL, Kohler C, Allison JJ, Kiefe CI, Volkman JE, Houston TK. Narratives to enhance smoking cessation interventions among African-American smokers, the ACCE project. BMC Research Notes 2015;8:567.26467316
Cheyenne River Sioux Tribe. Tribal memorandum re: Ordinance 77—The CRST Smoke-Free Clean Air Act of 2015, May 8, 2015; <http://goodandhealthysd.org/wp-content/uploads/2013/08/CRSTSmokeFreeAirAct.pdf>; accessed: July 8, 2022.
Chido-Amajuoyi OG, Ozigbu CE, Zhang K. School proximity and census tract correlates of e-cigarette specialty retail outlets (vape shops) in central Texas. Preventive Medicine Reports 2020;18:101079.32257777
Choi K, Soneji S, Tan ASL. Receipt of tobacco direct mail coupons and changes in smoking status in a nationally representative sample of U.S. adults. Nicotine & Tobacco Research 2018;20(9):1095–100.30124987
Choi WS, Beebe LA, Nazir N, Kaur B, Hopkins M, Talawyma M, Shireman TI, Yeh H-W, Greiner KA, Daley CM. All nations breath of life: a randomized trial of smoking cessation for American Indians. American Journal of Preventive Medicine 2016a;51(5):743–51.27436332
Choi WS, Nazir N, Pacheco CM, Filippi MK, Pacheco J, White Bull J, Nance C, Faseru B, Greiner KA, Daley CM. Recruitment and baseline characteristics of American Indian tribal college students participating in a tribal college tobacco and behavioral survey. Nicotine & Tobacco Research 2016b;18(6):1488–93.26438647
Chung-Hall J, Fong GT, Meng G, Cummings KM, Hyland A, O’Connor RJ, Quah ACK, Craig LV. Evaluating the impact of menthol cigarette bans on cessation and smoking behaviours in Canada: longitudinal findings from the Canadian arm of the 2016–2018 ITC Four Country Smoking and Vaping surveys. Tobacco Control 2022;31(4):556–63.33820856
Ciecierski CC, Chatterji P, Chaloupka FJ, Wechsler H. Do state expenditures on tobacco control programs decrease use of tobacco products among college students? Health Economics 2011;20(3):253–72.20069614
Cigar Association of America. v. U.S. Food & Drug Administration, 16-cv-01460, Docket No. 277 (D.D.C. Aug. 9, 2023).
City and County of San Francisco. Health Code—Restricting the Sale, Manufacture, and Distribution of Tobacco Products, Including Electronic Cigarettes (Ordinance No. 122-19, Article 19R), June 25, 2019; <https://sfgov.legistar.com/View.ashx?M=F&ID=7513894&GUID=8217F3A5-6B89-4B91-AEA1-02050399C0FE>; accessed: July 12, 2022.
Clattenburg EJ, Elf JL, Apelberg BJ. Unplanned cigarette purchases and tobacco point of sale advertising: a potential barrier to smoking cessation. Tobacco Control 2013;22(6):376–81.23138525
Cobb NK, Brookover J, Cobb CO. Forensic analysis of online marketing for electronic nicotine delivery systems. Tobacco Control 2013;24(2):128–31.24038037
Cokkinides VE, Halpern MT, Barbeau EM, Ward E, Thun MJ. Racial and ethnic disparities in smoking-cessation interventions: analysis of the 2005 National Health Interview Survey. American Journal of Preventive Medicine 2008;34(5):404–12.18407007
Cole AG, Aleyan S, Qian W, Leatherdale ST. Assessing the strength of secondary school tobacco policies of schools in the COMPASS study and the association to student smoking behaviours. Canadian Journal of Public Health 2019;110(2):236–43.30706437
Colman GJ, Remler DK. Vertical equity consequences of very high cigarette tax increases: if the poor are the ones smoking, how could cigarette tax increases be progressive? Journal of Policy Analysis and Management 2008;27(2):376–400.
Combs TB, McKay VR, Ornstein J, Mahoney M, Cork K, Brosi D, Kasman M, Heuberger B, Hammond RA, Luke D. Modelling the impact of menthol sales restrictions and retailer density reduction policies: insights from tobacco town Minnesota. Tobacco Control 2020;29(5):502–9.31462580
Comer JP. Educating poor minority children. Scientific American 1988;259(5):42–8.
Commune. Commune [home page], n.d.; <http://www.jointhecommune.com/>; accessed: December 15, 2022.
Community Preventive Services Task Force. Tobacco use: mass-reach health communication interventions, 2013; <https://www.thecommunityguide.org/findings/tobacco-use-mass-reach-health-communication-interventions>; accessed: July 31, 2022.
Connolly GN, Behm I, Healton CG, Alpert HR. Public attitudes regarding banning of cigarettes and regulation of nicotine. American Journal of Public Health 2012;102(4):e1–e2.
Connors E, Selove R, Canedo J, Sanderson M, Hull P, Adams M, McDermott I, Barlow C, Johns-Porter D, McAfee C, . Improving community advisory board engagement in precision medicine research to reduce health disparities. Journal of Health Disparities Research and Practice. 2019;12(6):80–94.32832256
Consolidated Appropriations Act, Public Law 117-103, Division P, Title I, Subtitle B, § 111, 136 STAT. 789 (2022).
Cooklin A, Joss N, Dupre-Husser E, Oldenburg B. Integrated approaches to occupational health and safety and health promotion: A systematic review. American Journal of Health Promotion 2016;31(5):401–12.26730561
Cooper M, Park-Lee E, Ren C, Cornelius M, Jamal A, Cullen KA. Notes from the field: e-cigarette use among middle and high school students—United States, 2022. Morbidity and Mortality Weekly Report 2022;71(40):1283–5.36201370
Cornelius ME, Driezen P, Fong GT, Chaloupka FJ, Hyland A, Bansal-Travers M, Carpenter MJ, Cummings KM. Trends in the use of premium and discount cigarette brands: findings from the ITC U.S. Surveys (2002-2011). Tobacco Control 2014;23 (Suppl 1):i48–i53.24092600
Cornelius ME, Loretan CG, Jamal A, Davis Lynn BC, Mayer M, Alcantara IC, Neff L. Tobacco product use among adults—United States, 2021. Morbidity and Mortality Weekly Report 2023a;72(18):475–83.37141154
Cornelius ME, Loretan CG, Jamal A, Davis Lynn BC, Mayer M, Alcantara IC, Neff L. Tobacco Product Use Among Adults - United States, 2021. Morbidity and Mortality Weekly Report 2023b;72(18):475–83.37141154
Cornelius ME, Loretan CG, Wang TW, Jamal A, Homa DM. Tobacco product use among adults—United States, 2020. Morbidity and Mortality Weekly Report 2022;71(11):397–405.35298455
Cotti CD, Courtemanche CJ, Maclean JC, Nesson ET, Pesko MF, Tefft N. The Effects of E-Cigarette Taxes on E-Cigarette Prices and Tobacco Product Sales: Evidence from Retail Panel Data. Working Paper 26724. Cambridge (MA): National Bureau of Economic Research, 2022.
CounterTobacco.org. Licensing, zoning, and retailer density, n.d.a; <https://countertobacco.org/policy/licensing-and-zoning/>; accessed: July 20, 2021.
CounterTobacco.org. Native Americans and point-of-sale commercial tobacco, n.d.b; <https://countertobacco.org/resources-tools/evidence-summaries/native-americans-point-of-sale/>; accessed: July 11, 2022.
Courtemanche CJ, Palmer MK, Pesko MF. Influence of the flavored cigarette ban on adolescent tobacco use. American Journal of Preventive Medicine 2017;52(5):e139–e146.28081999
Cousins R, MacKay CJ, Clarke SD, Kelly C, Kelly PJ, McCaig RH. Management standards’ work-related stress in the UK: practical development. Work and Stress 2004;18(2):113–36.
Cowell AJ, Farrelly MC, Chou R, Vallone DM. Assessing the impact of the national ‘truth’ antismoking campaign on beliefs, attitudes, and intent to smoke by race/ethnicity. Ethnicity & Health 2009;14(1):75–91.19152160
Cowgill BO, Herrmann A, Richardson J, Guthmann DS, Mckee MM, Malzkuhn M, Berman BA. Understanding e-cigarette knowledge and use among d/deaf and hard of hearing students and the need for tailored prevention programming: a qualitative study. American Annals of the Deaf 2020;165(3):335–52.
Coxe N, Webber W, Burkhart J, Broderick B, Yeager K, Jones L, Fenstersheib M. Use of tobacco retail permitting to reduce youth access and exposure to tobacco in Santa Clara County, California. Preventive Medicine 2014;67(Suppl 1):S46–S50.24513170
Craigmile PF, Onnen N, Schwartz E, Glasser A, Roberts ME. Evaluating how licensing-law strategies will impact disparities in tobacco retailer density: a simulation in Ohio. Tobacco Control 2021;30(e2):e96–e103.32826386
Crankshaw E, Gaber J, Guillory J, Curry L, Farrelly M, Saunders M, Delahanty J, Mekos D, Alexander T, Hoffman L, . Final evaluation findings for This Free Life, a 3-year, multi-market tobacco public education campaign for gender and sexual minority young adults in the United States. Nicotine & Tobacco Research 2022;24(1):109–17.34270739
Crawford VL. Cancer converts tobacco lobbyist: Victor L. Crawford goes on the record. Interview by Andrew A. Skolnick. JAMA: the Journal of the American Medical Association 1995;274(3):199–200, 202.7609213
Creamer MR, Wang TW, Babb S, Cullen KA, Day H, Willis G, Ahmed Jamal A, Neff L. Tobacco product use and cessation indicators among adults—United States, 2018. Morbidity and Mortality Weekly Report 2019;68(45):1013–9.
Crosbie E, Schmidt LA. Preemption in tobacco control: a framework for other areas of public health. American Journal of Public Health 2020;110(3):345–50.31944839
Croyle RT, Morgan GD, Fiore MC. Addressing a core gap in cancer care—the NCI Moonshot Program to help oncology patients stop smoking. New England Journal of Medicine 2019;380(6):512–5.30601710
Cruvinel E, Richter KP, Stoney C, Duffy S, Fellows J, Harrington KF, Rigotti NA, Sherman S, Tindle HA, Shireman TI, . CHARTing a path to pragmatic tobacco treatment research. American Journal of Preventive Medicine 2016;51(4):630–6.27647063
Cruz TB, Wright LT, Crawford G. The menthol marketing mix: targeted promotions for focus communities in the United States. Nicotine & Tobacco Research 2010;12(Suppl 2):S147–S153.21177371
Cummings KM, Fix B, Celestino P, Carlin-Menter S, O’Connor R, Hyland A. Reach, efficacy, and cost-effectiveness of free nicotine medication giveaway programs. Journal of Public Health Management and Practice 2006;12(1):37–43.16340514
Cummins SE, Bailey L, Campbell S, Koon-Kirby C, Zhu S-H. Tobacco cessation quitlines in North America: a descriptive study. Tobacco Control 2007;16(Suppl 1): i9–i15.18048639
Cummins SE, Kirby CA, Wong S, Anderson CM, Zhu SH. Re-engagement of low-income smokers in quitline services: effects of incentives and method of contact. Nicotine & Tobacco Research 2023;25(4):796–802.36271898
Cunradi CB, Moore RS, Battle RS, Yerger VB. Smoking, work stress, and barriers to participation in HMO smoking cessation treatment among transit workers: focus group results. Journal of Workplace Behavioral Health 2015;30(3):272–86.
Cuomo RE, Purushothaman VL, Li J, Bardier C, Nali M, Shah N, Obradovich N, Yang J, Mackey TK. Characterizing self-reported tobacco, vaping, and marijuana-related tweets geolocated for California college campuses. Frontiers in Public Health 2021;9:628812.33928062
Cupertino AP, Richter K, Cox LS, Garrett S, Ramirez R, Mujica F, Ellerbeck EF. Feasibility of a Spanish/English computerized decision aid to facilitate smoking cessation efforts in underserved communities. Journal of Health Care for the Poor and Underserved 2010;21(2):504–17.20453353
Curry SJ, Grothaus LC, McAfee T, Pabiniak C. Use and cost effectiveness of smoking-cessation services under four insurance plans in a health maintenance organization. New England Journal of Medicine 1998;339(10):673–9.9725926
CVS Health. Tobacco-free college campuses, March 18, 2019; <https://www.cvshealth.com/news/community/tobacco-free-college-campuses.html>; accessed: November 13, 2023.
Czaplicki L, Schillo B, Rose SW, Zhou Y, Vallone D. National support for a menthol cigarette sales ban. Public Health Reports 2022;137(3):605. [See also erratum in Public Health Reports 2022;137(3):605]33601979
Czogala J, Goniewicz ML, Fidelus B, Zielinska-Danch W, Travers MJ, Sobczak A. Secondhand exposure to vapors from electronic cigarettes. Nicotine & Tobacco Research 2014;16(6):655–62.24336346
D’Angelo H, Webb Hooper M, Burris JL, Rolland B, Adsit R, Pauk D, Rosenblum M, Fiore MC, Baker TB. Achieving equity in the reach of smoking cessation services within the NCI cancer moonshot—funded cancer center cessation initiative. Health Equity 2021;5(1):424–30.34235367
D’Silva J, Lien RK, Lachter R, Keller PA. Utilizing reach ratios to assess menthol cigarette smoker enrollment in quitline services. American Journal of Preventive Medicine 2021;60(3 Suppl 2):S123–S127.33663699
Dahne J, Nahhas GJ, Wahlquist AE, Cummings KM, Carpenter MJ. State tobacco excise taxation, comprehensive smoke-free air laws, and tobacco control appropriations as predictors of smoking cessation success in the United States. Journal of Public Health Management and Practice 2020a;26(5):E1–E4.
Dahne J, Wahlquist AE, Smith TT, Carpenter MJ. The differential impact of nicotine replacement therapy sampling on cessation outcomes across established tobacco disparities groups. Preventive Medicine 2020b;136:106096.32320705
Daley A, Rahman M, Watson B. A breath of fresh air: the effect of public smoking bans on Indigenous youth. Health Economics 2021a;30(6):1517–39.33860551
Daley A, Rahman M, Watson B. Racial/ethnic differences in light of 100% smoke-free state laws: evidence from adults in the United States. Population Health Management 2021b;24(3):353–9.32639185
Daley CM, Lewis C, Nazir N, Daley SM, Goeckner R, Hale J, Gunville J, Faseru B, Greiner KA, Choi WS. Pilot testing All Nations Snuff Out Smokeless (ANSOS): a culturally tailored smokeless tobacco cessation program for American Indians. Journal of Health Care for the Poor and Underserved 2021c;32(4):2154–66.34803065
Danan ER, Fu SS, Clothier BA, Noorbaloochi S, Hammett PJ, Widome R, Burgess DJ. The equity impact of proactive outreach to smokers: analysis of a randomized trial. American Journal of Preventive Medicine 2018;55(4):506–16.30139707
Darden ME, Hotchkiss JL, Melinda Pitts M. The dynamics of the smoking wage penalty. Journal of Health Economics 2021;79:102485.34273853
Dauchy E, Shang C. The pass-through of excise taxes to market prices of heated tobacco products (HTPs) and cigarettes: a cross-country analysis. The European Journal of Health Economics 2022.
David AM, Lew R, Lyman AK, Otto C, Robles R, Cruz GJ. Eliminating tobacco-related disparities among Pacific Islanders through leadership and capacity building: promising practices and lessons learned. Health Promotion Practice 2013;14(5 Suppl):10S–7S.23690256
Davis KC, Alexander RL Jr, Shafer P, Mann N, Malarcher A, Zhang L. The dose-response relationship between tobacco education advertising and calls to quitlines in the United States, March–June, 2012. Preventing Chronic Disease 2015;12:E191.26542143
Davis KC, Duke J, Shafer P, Patel D, Rodes R, Beistle D. Perceived effectiveness of antismoking ads and association with quit attempts among smokers: evidence from the Tips From Former Smokers campaign. Health Communication 2017;32(8):931–8.27435919
Davis KC, Patel D, Shafer P, Duke J, Glover-Kudon R, Ridgeway W, Cox S. Association between media doses of the Tips From Former Smokers campaign and cessation behaviors and intentions to quit among cigarette smokers, 2012–2015. Health Education & Behavior 2018;45(1):52–60.28497703
Davis KC, Shafer PR, Rodes R, Kim A, Hansen H, Patel D, Coln C, Beistle D. Does digital video advertising increase population-level reach of multimedia campaigns? Evidence from the 2013 Tips From Former Smokers Campaign. Journal of Medical Internet Research 2016;18(9):e235.27627853
de Andrade M, Hastings G, Angus K. Promotion of electronic cigarettes: tobacco marketing reinvented? BMJ 2013;347:f7473.24361526
Dearlove JV, Bialous SA, Glantz SA. Tobacco industry manipulation of the hospitality industry to maintain smoking in public places. Tobacco Control 2002;11(2):94–104.12034999
DeCicca P, Kenkel D, Liu F. Reservation prices: an economic analysis of cigarette purchases on Indian reservations. National Tax Journal 2015;68(1):93–118.
DeCicca P, McLeod L. Cigarette taxes and older adult smoking: evidence from recent large tax increases. Journal of Health Economics 2008;27(4):918–29.18178277
Delahanty J, Ganz O, Bernat JK, Trigger S, Smith A, Lavinghouze R, Rao P. Awareness of “The Real Cost” campaign among U.S. middle and high school students: National Youth Tobacco Survey. Public Health Reports 2019;135(1):82–9.
Delgado-Rendón A, Cruz TB, Soto D, Baezconde-Garbanati L, Unger JB. Second and thirdhand smoke exposure, attitudes and protective practices: results from a survey of Hispanic residents in multi-unit housing. Journal of Immigrant and Minority Health 2017;19(5):1148–55.28074306
Denlinger-Apte RL, Joel DL, Strasser AA, Donny EC. Low nicotine content descriptors reduce perceived health risks and positive cigarette ratings in participants using very low nicotine content cigarettes. Nicotine & Tobacco Research 2017;19(10):1149–54.28003507
Denlinger-Apte RL, Kotlyar M, Koopmeiners JS, Tidey JW, Luo X, Benowitz NL, Jensen JA, Ikuemonisan JO, Pacek LR, Smith TT, . Effects of very low nicotine content cigarettes on smoking behavior and biomarkers of exposure in menthol and non-menthol smokers. Nicotine & Tobacco Research 2019;21(Suppl 1):S63–S72.31867637
Denlinger-Apte RL, Pacek LR, Ross JC, Bansal-Travers M, Donny EC, Hatsukami DK, Carroll DM. Risk perceptions of low nicotine cigarettes and alternative nicotine products across priority smoking populations. International Journal of Environmental Research and Public Health 2021;18(10):5311.34067652
Derefinko KJ, Bursac Z, Mejia MG, Milich R, Lynam DR. Rural and urban substance use differences: effects of the transition to college. American Journal of Drug and Alcohol Abuse 2018;44(2):224–34.28726520
Deverell M, Randolph C, Albers A, Hamilton W, Siegel M. Diffusion of local restaurant smoking regulations in Massachusetts: identifying disparities in health protection for population subgroups. Journal of Public Health Management and Practice 2006;12(3):262–9.16614562
Diaz MC, Kierstead EC, Khatib BS, Schillo BA, Tauras JA. Investigating the impact of e-cigarette price and tax on e-cigarette use behavior. American Journal of Preventive Medicine 2023.
Dickerson FB, Savage CL, Schweinfurth LA, Medoff DR, Goldberg RW, Bennett M, Lucksted A, Chinman M, Daumit G, Dixon L, . The use of peer mentors to enhance a smoking cessation intervention for persons with serious mental illnesses. Psychiatric Rehabilitation Journal 2016;39(1):5–13.26461436
DiGiulio A, Haddix M, Jump Z, Babb S, Schecter A, Williams KS, Asman K, Armour BS. State Medicaid expansion tobacco cessation coverage and number of adult smokers enrolled in expansion coverage—United States, 2016. Morbidity and Mortality Weekly Report 2016;65(48):1364–9.27932786
DiGiulio A, Jump Z, Babb S, Schecter A, Williams KS, Yembra D, Armour BS. State Medicaid coverage for tobacco cessation treatments and barriers to accessing treatments—United States, 2008–2018. Morbidity and Mortality Weekly Report 2020;69(6):155–60.32053583
Dignan MB, Jones K, Burhansstipanov L, Ahamed SI, Krebs LU, Williams D, Ahsan GMT, Addo I, Sargent M, Cina K, . A randomized trial to reduce smoking among American Indians in South Dakota: The walking forward study. Contemporary Clinical Trials 2019;81:28–33.30986536
Dilley JA, Otero M, Padilla JL, Costello H, Turietta T, Jacquez B. DEJELO YA media campaign connects Spanish-speaking communities to effective support for quitting tobacco. Health Promotion Practice 2020; 21(1 Suppl):89S–97S.31908206
Dinno A, Glantz S. Tobacco control policies are egalitarian: a vulnerabilities perspective on clean indoor air laws, cigarette prices, and tobacco use disparities. Social Science & Medicine 2009;68(8):1439–47.19282078
Do EK, Fallavollita WL, Bonat B, Fugate-Laus K, Rossi BC, Fuemmeler BF. Student attitudes toward tobacco use and tobacco policies on college campuses. Journal of Community Health 2020;45(4):751–60.31925604
Dobbs PD, Hammig B, Henry LJ. E-cigarette use among U.S. adolescents: perceptions of relative addiction and harm. Health Education Journal 2017;76(3):293–301.
Donny EC, Denlinger RL, Tidey JW, Koopmeiners JS, Benowitz NL, Vandrey RG, al’Absi M, Carmella SG, Cinciripini PM, Dermody SS, . Randomized trial of reduced-nicotine standards for cigarettes. New England Journal of Medicine 2015;373(14):1340–9.26422724
Donny EC, White CM. A review of the evidence on cigarettes with reduced addictiveness potential. International Journal on Drug Policy 2022;99:103436.34535366
Donovan E, Folger S, Akbar M, Schillo B. Classifying the comprehensiveness of flavoured tobacco sales restrictions: development and application of a tool to examine U.S. state and local tobacco policies. Tobacco Control 2021.
Doogan NJ, Wewers ME, Berman M. The impact of a federal cigarette minimum pack price policy on cigarette use in the USA. Tobacco Control 2018;27(2):203–8.28259846
Dorilas E, Hill SC, Pesko MF. Tobacco surcharges associated with reduced ACA marketplace enrollment. Health Affairs 2022;41(3):398–405.35254928
Dove MS, Stewart SL, Cummins SE, Kohatsu ND, Tong EK. Medi-Cal Incentives to Quit Smoking Program: reach to pregnant and parenting women. American Journal of Preventive Medicine 2018;55(6 Suppl 2):S205–S213.30454675
Driezen P, Fong GT, Hyland A, Craig LV, Sansone G, Hitchman SC, Cummings KM. Self-reported exposure to secondhand smoke and support for complete smoking bans in multiunit housing among smokers in the United States, Canada, and the United Kingdom. Preventing Chronic Disease 2020;17:E147.33241991
Drope J, Schluger N, Cahn Z, Drope J, Hamill S, Islami F, Liber A, Nargis N, Stoklosa M. The Tobacco Atlas. 6th ed. Atlanta (GA): American Cancer Society and Vital Strategies, 2018.
Duke JC, Alexander TN, Zhao X, Delahanty JC, Allen JA, MacMonegle AJ, Farrelly MC. Youth’s awareness of and reactions to The Real Cost national tobacco public education campaign. PLoS One 2015a;10(12):e0144827.26679504
Duke JC, Davis KC, Alexander RL, MacMonegle AJ, Fraze JL, Rodes RM, Beistle DM. Impact of a U.S. antismoking national media campaign on beliefs, cognitions and quit intentions. Health Education Research 2015b;30(3):466–83.25976009
Duke JC, MacMonegle AJ, Nonnemaker JM, Farrelly MC, Delahanty JC, Zhao X, Smith AA, Rao P, Allen JA. Impact of The Real Cost media campaign on youth smoking initiation. American Journal of Preventive Medicine 2019;57(5):645–51.31443954
Duke JC, Vallone DM, Allen JA, Cullen J, Mowery PD, Xiao H, Dorrler N, Asche ET, Healton C. Increasing youths’ exposure to a tobacco prevention media campaign in rural and low-population-density communities. American Journal of Public Health 2009;99(12):2210–6.19833994
Dunlop SM. Talking “truth”: predictors and consequences of conversations about a youth antismoking campaign for smokers and nonsmokers. Journal of Health Communication 2011;16(7):708–25.21476165
Durkin S, Brennan E, Wakefield M. Mass media campaigns to promote smoking cessation among adults: an integrative review. Tobacco Control 2012;21(2):127–38.22345235
Eakin MN, Rand CS, Borrelli B, Bilderback A, Hovell M, Riekert KA. Effectiveness of motivational interviewing to reduce head start children’s secondhand smoke exposure. A randomized clinical trial. American Journal of Respiratory and Critical Care Medicine 2014;189(12):1530–7.24821270
Eguia E, Cobb AN, Kothari AN, Molefe A, Afshar M, Aranha GV, Kuo PC. Impact of the Affordable Care Act (ACA) Medicaid expansion on cancer admissions and surgeries. Annals of Surgery 2018;268(4):584–90.30004928
Eisenberg MJ, Windle SB, Roy N, Old W, Grondin FR, Bata I, Iskander A, Lauzon C, Srivastava N, Clarke A, . Varenicline for smoking cessation in hospitalized patients with acute coronary syndrome. Circulation 2016;133(1):21–30.26553744
El-Toukhy S, Choi K, Hitchman SC, Bansal-Travers M, Thrasher JF, Yong H-H, O’Connor RJ, Shang C. Banning tobacco price promotions, smoking-related beliefs and behaviour: findings from the International Tobacco Control Four Country (ITC 4C) Survey. Tobacco Control 2018;27(3):310–8.28701585
Ellerbeck EF, Mahnken JD, Cupertino AP, Cox LS, Greiner KA, Mussulman LM, Nazir N, Shireman TI, Resnicow K, Ahluwalia JS. Effect of varying levels of disease management on smoking cessation: a randomized trial. Annals of Internal Medicine 2009;150(7):437–46.19349629
Elliot DL, Goldberg L, Kuehl KS, Moe EL, Breger RK, Pickering MA. The PHLAME (Promoting Healthy Lifestyles: Alternative Models’ Effects) firefighter study: outcomes of two models of behavior change. Journal of Occupational and Environmental Medicine 2007;49(2):204–13.17293760
Emmons KM, Barbeau EM, Gutheil C, Stryker JE, Stoddard AM. Social influences, social context, and health behaviors among working-class, multi-ethnic adults. Health Education & Behavior 2007;34(2):315–34.16740510
England L, Tong VT, Rockhill K, Hsia J, McAfee T, Patel D, Rupp K, Conrey EJ, Valdivieso C, Davis KC. Evaluation of a federally funded mass media campaign and smoking cessation in pregnant women: a population-based study in three states. BMJ Open 2017;7(12):e016826.
Eshraghian EA, Al-Delaimy WK. A review of constituents identified in e-cigarette liquids and aerosols. Tobacco Prevention & Cessation 2021;7:10.33585727
European Network for Workplace Health Promotion. The Luxembourg declaration on workplace health promotion in the European Union. Presentation at the meeting of the European Network for Workplace Health Promotion; November 27–28, 1997; Luxembourg.
Evans WD, Thomas CN, Favatas D, Smyser J, Briggs J. Digital segmentation of priority populations in public health. Health Education & Behavior 2019;46(2 Suppl):81–9.31742454
Evans WN, Farrelly MC, Montgomery E. Do workplace smoking bans reduce smoking? American Economic Review 1999;89(4):728–47.
Fahmy N. Ohio Senate blocks cities from banning flavored tobacco, January 25, 2024; <https://www.nbc4i.com/news/local-news/columbus/ohio-senate-blocks-cities-from-banning-flavored-tobacco/>; accessed: April 11, 2024.
Fakunle DO, Thorpe RJ Jr, Furr-Holden CDM, Curriero FC, Leaf PJ. Does tobacco outlet inequality extend to high-white mid-Atlantic jurisdictions? A study of socioeconomic status and density. Journal of Racial and Ethnic Health Disparities 2019;6(2):409–18.30446987
Fallin A, Lee YO, Bennett K, Goodin A. Smoking cessation awareness and utilization among lesbian, gay, bisexual, and transgender adults: an analysis of the 2009–2010 National Adult Tobacco Survey. Nicotine & Tobacco Research 2016;18(4):496–500.26014455
Fallin A, Murrey M, Johnson AO, Riker CA, Rayens MK, Hahn EJ. Measuring compliance with tobacco-free campus policy. Journal of American College Health 2012;60(7):496–504.23002797
Fallin A, Neilands TB, Jordan JW, Hong JS, Ling PM. Wreaking “havoc” on smoking: social branding to reach young adult “partiers” in Oklahoma. American Journal of Preventive Medicine 2015a;48(1 Suppl 1):S78–S85.25528713
Fallin A, Neilands TB, Jordan JW, Ling PM. Social branding to decrease lesbian, gay, bisexual, and transgender young adult smoking. Nicotine & Tobacco Research 2015b;17(8):983–9.26180223
Fallin A, Roditis M, Glantz SA. Association of campus tobacco policies with secondhand smoke exposure, intention to smoke on campus, and attitudes about outdoor smoking restrictions. American Journal of Public Health 2015c;105(6):1098–100.25521901
Family Smoking Prevention and Tobacco Control Act, Public Law 111–31, 123 U.S. Statutes at Large 1776 (2009).
Farley SM, Jasek J, Debchoudhury I, Van Beck K, Talati A, Perlman SE, Thorpe LE. Housing type and secondhand tobacco smoke exposure among non-smoking New York City adults, 2004 and 2013–14. Preventive Medicine Reports 2022;27:101805.35656213
Farley SM, Johns M. New York City flavoured tobacco product sales ban evaluation. Tobacco Control 2017;26(1):78–84.26872486
Farley SM, Waddell EN, Coady MH, Grimshaw V, Wright DA, Mandel-Ricci J, Kansagra SM. Correlates of smoke-free housing policies and interest in implementing policies among multiunit housing owners in New York City. Journal of Urban Health 2015;92(2):291–303.25670210
Farrelly MC, Bray JW, Pechacek T, Woollery T. Response by adults to increases in cigarette prices by sociodemographic characteristics. Southern Economic Journal 2001;68(1):156–65.
Farrelly MC, Engelen M. Cigarette prices, smoking, and the poor, revisited. American Journal of Public Health 2008;98(4):582–3; author reply 3–4.
Faseru B, Ellerbeck EF, Catley D, Gajewski BJ, Scheuermann TS, Shireman TI, Mussulman LM, Nazir N, Bush T, Richter KP. Changing the default for tobacco-cessation treatment in an inpatient setting: study protocol of a randomized controlled trial. Trials 2017;18(1):379.28806908
Faseru B, Richter KP, Scheuermann TS, Park EW. Enhancing partner support to improve smoking cessation. Cochrane Database of Systematic Reviews 2018, Issue 8. Art. No.: CD002928. DOI: 10.1002/14651858.CD002928.pub4.
Faseru B, Yeh H-W, Ellerbeck EF, Befort C, Richter KP. Prevalence and predictors of tobacco treatment in an academic medical center. Joint Commission Journal on Quality and Patient Safety 2009;35(11):551–7.19947331
Federal Communications Commission. Inquiry Concerning Deployment of Advanced Telecommunications Capability to All Americans in a Reasonable and Timely Fashion, January 19, 2021; <https://docs.fcc.gov/public/attachments/FCC-21-18A1.pdf>; accessed: July 31, 2022.
Federal Register. Centers for Medicare & Medicaid Services, U.S. Department of Health and Human Services. Medicare and Medicaid programs; Electronic Health Record Incentive Program; final rule (42 CFR Parts 412, 413, 422, and 495). 75 Fed. Reg. 44314 (2010).
Federal Register. Centers for Medicare & Medicaid Services, U.S. Department of Health and Human Services. Medicare program; FY 2024 Inpatient Psychiatric Facilities Prospective Payment System—rate update; final rule (42 CFR Part 412). 88 Fed. Reg. 147 (2023a).
Federal Register. Centers for Medicare & Medicaid Services, U.S. Department of Health and Human Services. Medicare Program; hospital inpatient Prospective Payment Systems for acute care hospitals and the long-term care hospital Prospective Payment System and policy changes and fiscal year 2024 rates; quality programs and Medicare promoting interoperability program requirements for eligible hospitals and critical access hospitals; rural emergency hospital and physician-owned hospital requirements; and provider and supplier disclosure of ownership; and Medicare disproportionate Share Hospital (DSH) payments: counting certain days associated with Section 1115 demonstrations in the Medicaid fraction; final rules. (42 CFR Parts 411, 412, 419, 488, 489, and 495). 88 Fed. Reg. 58640 (2023b).
Federal Register. Office of the Assistant Secretary for Public and Indian Housing, U.S. Department of Housing and Urban Development. Instituting smoke-free public housing, 81 Fed. Reg. 87430 (2016a); <https://www.federalregister.gov/documents/2016/12/05/2016-28986/instituting-smoke-free-public-housing>; accessed: April 20, 2020.
Federal Register. U.S. Department of Health and Human Services, Centers for Medicare & Medicaid Services. Medicare and Medicaid programs; Electronic Health Record Incentive Program—Stage 2; final rule (42 CFR Parts 412, 413, and 495), 77 Fed. Reg. 53968 (2012).
Federal Register. U.S. Department of Health and Human Services, U.S. Food and Drug Administration. Tobacco product standard for nicotine level of combusted cigarettes, 83 Fed. Reg. 11818 (2018).
Federal Register. U.S. Department of Health and Human Services, U.S. Food and Drug Administration. Tobacco products; required warnings for cigarette packages and advertisements; final rule (21 CFR Part 1141), 85 Fed. Reg. 15638 (2020).
Federal Register. U.S. Department of Health and Human Services, Food and Drug Administration. Deeming tobacco products to be subject to the Federal Food, Drug, and Cosmetic Act, as amended by the Family Smoking Prevention and Tobacco Control Act; restrictions on the sale and distribution of tobacco products and required warning statements for tobacco products, 81 Fed. Reg. 28973 (2016b); <https://www.federalregister.gov/d/2016-10685>; accessed: February 19, 2019.
Federal Register. Centers for Medicare & Medicaid Services, U.S. Department of Health and Human Services. Medicare Program; hospital inpatient Prospective Payment Systems for acute care hospitals and the long-term care hospital Prospective Payment System and policy changes and fiscal year 2023 rates; quality programs and Medicare promoting interoperability program requirements for eligible hospitals and critical access hospitals; costs incurred for qualified and non-qualified deferred compensation plans; and changes to hospital and critical access hospital conditions of participation; final rule. (42 CFR Parts 412, 413, 482, 485, and 495). 87 Fed. Reg. 48780 (2022a).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Tobacco product standard for menthol in cigarettes (proposed product standard) (21 CFR 1162), 87 Fed. Reg. 26454 (2022b).
Federal Trade Commission. Federal Trade Commission Cigarette Report for 2019. Washington (DC): U.S. Department of Commerce, 2021.
Fellows JL, Bush T, McAfee T, Dickerson J. Cost effectiveness of the Oregon quitline “free patch initiative”. Tobacco Control 2007;16(Suppl 1):i47–i52.18048632
Feltner C, Peterson K, Weber RP, Cluff L, Coker-Schwimmer E, Viswanathan M, Lohr KN. The effectiveness of total worker health interventions: a systematic review for a National Institutes of Health Pathways to Prevention Workshop. Annals of Internal Medicine 2016;165(4):262–9.27240022
Ferguson J, Docherty G, Bauld L, Lewis S, Lorgelly P, Boyd KA, McEwen A, Coleman T. Effect of offering different levels of support and free nicotine replacement therapy via an English national telephone quitline: randomised controlled trial. BMJ 2012;344:e1696.22446739
Ferketich AK, Liber A, Pennell M, Nealy D, Hammer J, Berman M. Clean indoor air ordinance coverage in the Appalachian region of the United States. American Journal of Public Health 2010;100(7):1313–8.20466957
Fichtenberg CM, Glantz SA. Effect of smoke-free workplaces on smoking behaviour: systematic review. BMJ 2002;325(7357):188.12142305
Fiore MC, D’Angelo H, Baker T. Effective cessation treatment for patients with cancer who smoke—the fourth pillar of cancer care. JAMA Network Open 2019;2(9):e1912264.31560380
Fiore MC, Jaén CR, Baker TB, Bailey WC, Benowitz NL, Curry SJ, Dorfman SF, Froelicher ES, Goldstein MG, Healton CG, . Treating Tobacco Use and Dependence: 2008 Update. U.S. Public Health Service Clinical Practice Guideline. Rockville (MD): U.S. Department of Health and Human Services, 2008.
Fix BV, O’Connor RJ, Fong GT, Borland R, Cummings KM, Hyland A. Smokers’ reactions to FDA regulation of tobacco products: findings from the 2009 ITC United States survey. BMC Public Health 2011;11:941.22177316
Flay BR. The promise of long-term effectiveness of school-based smoking prevention programs: a critical review of reviews. Tobacco Induced Diseases 2009a;5(1):7.19323827
Flay BR. School-based smoking prevention programs with the promise of long-term effects. Tobacco Induced Diseases 2009b;5(1):6.19323826
Flay BR, Collins LM. Historical review of school-based randomized trials for evaluating problem behavior prevention programs. The Annals of the American Academy of Political and Social Science 2005;599(1):115.
Fleischer NL, Donahoe JT, McLeod MC, Thrasher JF, Levy DT, Elliott MR, Meza R, Patrick ME. Taxation reduces smoking but may not reduce smoking disparities in youth. Tobacco Control 2021;30(3):264–72.32269173
Flocke SA, Hoffman R, Eberth JM, Park H, Birkby G, Trapl E, Zeliadt S. The prevalence of tobacco use at federally qualified health centers in the United States, 2013. Preventing Chronic Disease 2017;14:E29.28384096
Flouris AD, Chorti MS, Poulianiti KP, Jamurtas AZ, Kostikas K, Tzatzarakis MN, Wallace Hayes A, Tsatsakis AM, Koutedakis Y. Acute impact of active and passive electronic cigarette smoking on serum cotinine and lung function. Inhalation Toxicology 2013;25(2):91–101.23363041
Flynn BS, Worden JK, Bunn JY, Solomon LJ, Ashikaga T, Connolly SW, Ramirez AG. Mass media interventions to reduce youth smoking prevalence. American Journal of Preventive Medicine 2010;39(1):53–62.20537841
Flynn JP, Gascon G, Doyle S, Matson Koffman DM, Saringer C, Grossmeier J, Tivnan V, Terry P. Supporting a culture of health in the workplace: a review of evidence-based elements. American Journal of Health Promotion 2018;32(8):1755–88.29806469
Fong GT, Chung-Hall J, Meng G, Craig LV, Thompson ME, Quah ACK, Cummings KM, Hyland A, O’Connor RJ, Levy DT, . Impact of Canada’s menthol cigarette ban on quitting among menthol smokers: pooled analysis of pre-post evaluation from the ITC Project and the Ontario Menthol Ban Study and projections of impact in the USA. Tobacco Control 2022.
Fortmann AL, Romero RA, Sklar M, Pham V, Zakarian J, Quintana PJ, Chatfield D, Matt GE. Residual tobacco smoke in used cars: futile efforts and persistent pollutants. Nicotine & Tobacco Research 2010;12(10):1029–36.20805293
Foulds J, Veldheer S, Pachas G, Hrabovsky S, Hameed A, Allen SI, Cather C, Azzouz N, Yingst J, Hammett E, . The effects of reduced nicotine content cigarettes on biomarkers of nicotine and toxicant exposure, smoking behavior and psychiatric symptoms in smokers with mood or anxiety disorders: A double-blind randomized trial. PLoS One 2022;17(11):e0275522.36322562
Fraser DL, Fiore MC, Kobinsky K, Adsit R, Smith SS, Johnson ML, Baker TB. A randomized trial of incentives for smoking treatment in Medicaid members. American Journal of Preventive Medicine 2017;53(6):754–63.29079405
Freudenberg N. Community capacity for environmental health promotion: determinants and implications for practice. Health Education & Behavior 2004;31(4):472–90.15296630
Freund J. Beyond the bargaining table: how unions help more than just their members. November 16, 2022; <https://blog.dol.gov/2022/11/16/beyond-the-bargaining-table-how-unions-help-more-than-just-their-members#:~:text=Workers%20covered%20by%20a%20negotiated,than%20those%20who%20are%20not>; accessed: June 16, 2023.
Frieden TR, Mostashari F, Kerker BD, Miller N, Hajat A, Frankel M. Adult tobacco use levels after intensive tobacco control measures: New York City, 2002–2003. American Journal of Public Health 2005;95(6):1016–23.15914827
Friedman AS, Horn SJL. Socioeconomic disparities in electronic cigarette use and transitions from smoking. Nicotine & Tobacco Research 2019;21(10):1363–70.29917124
Froelicher ES, Doolan D, Yerger VB, McGruder CO, Malone RE. Combining community participatory research with a randomized clinical trial: the Protecting the Hood Against Tobacco (PHAT) smoking cessation study. Heart & Lung 2010;39(1):50–63.20109986
Fu SS, Rhodes KL, Robert C, Widome R, Forster JL, Joseph AM. Designing and evaluating culturally specific smoking cessation interventions for American Indian communities. Nicotine & Tobacco Research 2014a;16(1):42–9.23892826
Fu SS, van Ryn M, Nelson D, Burgess DJ, Thomas JL, Saul J, Clothier B, Nyman JA, Hammett P, Joseph AM. Proactive tobacco treatment offering free nicotine replacement therapy and telephone counselling for socioeconomically disadvantaged smokers: a randomised clinical trial. Thorax 2016;71(5):446–53.26931362
Fu SS, van Ryn M, Sherman SE, Burgess DJ, Noorbaloochi S, Clothier B, Taylor BC, Schlede CM, Burke RS, Joseph AM. Proactive tobacco treatment and population-level cessation: a pragmatic randomized clinical trial. JAMA Internal Medicine 2014b;174(5):671–7.24615217
Fuchs T, Marquez A, Dutta PV, Gonzalez Icaza F. Is Tobacco Taxation Regressive? Evidence on Public Health, Domestic Resource Mobilization, and Equity Improvements, 2019; <http://documents.worldbank.org/curated/en/893811554737147697/Is-Tobacco-Taxation-Regressive-Evidence-on-Public-Health-Domestic-Resource-Mobilization-and-Equity-Improvements>; accessed: July 18, 2022.
Galanti MR, Coppo A, Jonsson E, Bremberg S, Faggiano F. Anti-tobacco policy in schools: upcoming preventive strategy or prevention myth? A review of 31 studies. Tobacco Control 2014;23(4):295–301.23716172
Galobardes B, Shaw M, Lawlor DA, Lynch JW, Davey Smith G. Indicators of socioeconomic position (part 1). Journal of Epidemiology and Community Health 2006;60(1):7–12.
Gammon DG, Rogers T, Gaber J, Nonnemaker JM, Feld AL, Henriksen L, Johnson TO, Kelley T, Andersen-Rodgers E. Implementation of a comprehensive flavoured tobacco product sales restriction and retail tobacco sales. Tobacco Control 2021.
Ganz O, King JL, Giovenco DP, Hrywna M, Strasser AA, Delnevo CD. Associations between Black and Mild cigar pack size and demographics and tobacco use behaviors among U.S. adults. International Journal of Environmental Research and Public Health 2021;18(12):6628.34202992
Garcia MC, Faul M, Massetti G, Thomas CC, Hong Y, Bauer UE, Iademarco MF. Reducing potentially excess deaths from the five leading causes of death in the rural United States. Morbidity and Mortality Weekly Report Surveillance Summaries 2017;66(2):1–7.
Garrett BE, Dube SR, Babb S, McAfee T. Addressing the social determinants of health to reduce tobacco-related disparities. Nicotine & Tobacco Research 2015;17(8):892–7.25516538
Gentzke AS, Hyland A, Kiviniemi M, Travers MJ. Attitudes and experiences with secondhand smoke and smokefree policies among subsidised and market-rate multiunit housing residents living in six diverse communities in the USA. Tobacco Control 2018;27(2):194–202.28302920
Gentzke AS, Wang TW, Cornelius M, Park-Lee E, Ren C, Sawdey MD, Cullen KA, Loretan C, Jamal A, Homa DM. Tobacco product use and associated factors among middle and high school students—National Youth Tobacco Survey, United States, 2021. Morbidity and Mortality Weekly Report Surveillance Summaries 2022;71(5):1–29.
Germain D, McCarthy M, Wakefield M. Smoker sensitivity to retail tobacco displays and quitting: a cohort study. Addiction 2010;105(1):159–63.19804457
Getty CA, Morande A, Lynskey M, Weaver T, Metrebian N. Mobile telephone-delivered contingency management interventions promoting behaviour change in individuals with substance use disorders: a meta-analysis. Addiction 2019;114(11):1915–25.31265747
Gingiss PM, Boerm M, Huang P, Hermer L. Smoke-free ordinances in Texas worksites, restaurants, and bars, 2000–2007. American Journal of Preventive Medicine 2009;36(2):91–5.19062236
Giovacchini CX, Pacek L, McClernon FJ, Que LG. Use and perceived risk of electronic cigarettes among North Carolina middle and high school students. North Carolina Medical Journal 2017;78(1):7–13.28115555
Giovenco DP, Spillane TE, Mauro CM, Hernandez D. Evaluating the impact and equity of a tobacco-free pharmacy law on retailer density in New York City neighbourhoods. Tobacco Control 2019;28(5):548–54.30135112
Givel MS, Glantz SA. Tobacco lobby political influence on U.S. state legislatures in the 1990s. Tobacco Control 2001;10(2):124–34.11387532
Glantz S, Alamar B. Correction to Mandel L, BC Alamar, SA Glantz. Smoke-free law did not affect revenue from gaming in Delaware. Tobacco Control 2005;14(360).
Glantz SA, Johnson KC. The surgeon general report on smoking and health 50 years later: breast cancer and the cost of increasing caution. Cancer Epidemiology, Biomarkers & Prevention 2014;23(1):37–46.
Glasgow TE, Miller CA, Barsell DJ, Do EK, Fuemmeler BF. Assessing how a tobacco-free campus leads to attitude change and support among students, faculty, and staff. Tobacco Prevention & Cessation 2021;7:53.34307968
Glasser AM, Roberts ME. Retailer density reduction approaches to tobacco control: a review. Health & Place 2021;67:102342.33526207
Goetzel RZ. Examining the value of integrating occupational health and safety and health promotion programs in the workplace. In: Research Compendium: The NIOSH Total Worker Health Program: Seminal Research Papers 2012. Washington (DC): Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health, 2012:66–107. DHHS (NIOSH) Publication No. 2012-146.
Goetzel RZ, Guindon AM, Turshen IJ, Ozminkowski RJ. Health and productivity management: establishing key performance measures, benchmarks, and best practices. Journal of Occupational and Environmental Medicine 2001;43(1):10–7.11201763
Golden SD, Baggett CD, Kuo T-M, Kong AY, Delamater PL, Tao VQ, Ribisl KM. Trends in the number and type of tobacco product retailers, United States, 2000–2017. Nicotine & Tobacco Research 2022;24(1):77–84.34302488
Golden SD, Smith MH, Feighery EC, Roeseler A, Rogers T, Ribisl KM. Beyond excise taxes: a systematic review of literature on non-tax policy approaches to raising tobacco product prices. Tobacco Control 2016;25(4):377–85.26391905
Goldenson NI, Leventhal AM, Simpson KA, Barrington-Trimis JL. A review of the use and appeal of flavored electronic cigarettes. Current Addiction Reports 2019;6(2):98–113.31453046
Goniewicz ML, Knysak J, Gawron M, Kosmider L, Sobczak A, Kurek J, Prokopowicz A, Jablonska-Czapla M, Rosik-Dulewska C, Havel C, . Levels of selected carcinogens and toxicants in vapour from electronic cigarettes. Tobacco Control 2014;23(2):133–9.23467656
Goniewicz ML, Smith DM, Edwards KC, Blount BC, Caldwell KL, Feng J, Wang L, Christensen C, Ambrose B, Borek N, . Comparison of nicotine and toxicant exposure in users of electronic cigarettes and combustible cigarettes. JAMA Network Open 2018;1(8):e185937.30646298
Gonzalez M, Sanders-Jackson A, Song AV, Cheng KW, Glantz SA. Strong smoke-free law coverage in the United States by race/ethnicity: 2000–2009. American Journal of Public Health 2013;103(5):e62–e66.23488507
Gorovitz E, Mosher J, Pertschuk M. Preemption or prevention? Lessons from efforts to control firearms, alcohol, and tobacco. Journal of Public Health Policy 1998;19(1):36–50.9581429
Grana R, Benowitz N, Glantz SA. Background paper on e-cigarettes (electronic nicotine delivery systems), 2013; <https://escholarship.org/uc/item/13p2b72n>; accessed: April 16, 2020.
Gray N, Halstead M, Valentin-Blasini L, Watson C, Pappas RS. Toxic metals in liquid and aerosol from pod-type electronic cigarettes. Journal of Analytical Toxicology 2020.
Gruber J, Koszegi B. Tax incidence when individuals are time-inconsistent: the case of cigarette excise taxes. Journal of Public Economics 2004;88(9–10):1959–87.
Gruber J, Zinman J. Youth smoking in the United States: evidence and implications. In: Gruber J, editor. Risky Behavior among Youths: An Economic Analysis. Chicago (IL): University of Chicago Press, 2001:69–120.
Guillaumier A, Bonevski B, Paul C. Anti-tobacco mass media and socially disadvantaged groups: a systematic and methodological review. Drug and Alcohol Review 2012;31(5):698–708.22571783
Guillory J, Curry L, Farrelly M, Henes A, Homsi G, Saunders M, MacMonegle A, Fiacco L, Alexander T, Delahanty J, . Reach, receptivity, and beliefs associated with the Fresh Empire campaign to prevent and reduce cigarette use among youth in the United States. American Journal of Health Promotion 2022;36(5):789–800.35081751
Guillory J, Henes A, Farrelly MC, Fiacco L, Alam I, Curry L, Ganz O, Hoffman L, Delahanty J. Awareness of and receptivity to the Fresh Empire tobacco public education campaign among hip hop youth. Journal of Adolescent Health 2020;66(3):301–7.
Gupta S, Scheuter C, Kundu A, Bhat N, Cohen A, Facente SN. Smoking-cessation interventions in Appalachia: a systematic review and meta-analysis. American Journal of Preventive Medicine 2020;58(2): 261–9.31740013
Guydish JR, Straus ER, Le T, Gubner N, Delucchi KL. Menthol cigarette use in substance use disorder treatment before and after implementation of a county-wide flavoured tobacco ban. Tobacco Control 2021;30(6):616–22.33177211
Guzman A, Walsh MC, Smith SS, Malecki KC, Nieto FJ. Evaluating effects of statewide smoking regulations on smoking behaviors among participants in the Survey of the Health of Wisconsin. WMJ 2012;111(4):166–71; quiz 72.22970531
Haardörfer R, Kreuter M, Berg CJ, Escoffery C, Bundy LT, Hovell M, Mullen PD, Williams R, Kegler MC. Cessation and reduction in smoking behavior: impact of creating a smoke-free home on smokers. Health Education Research 2018;33(3):256–9.29788227
Haas JS, Linder JA, Park ER, Gonzalez I, Rigotti NA, Klinger EV, Kontos EZ, Zaslavsky AM, Brawarsky P, Marinacci LX, . Proactive tobacco cessation outreach to smokers of low socioeconomic status: a randomized clinical trial. JAMA Internal Medicine 2015;175(2):218–26.25506771
Hafez AY, Gonzalez M, Kulik MC, Vijayaraghavan M, Glantz SA. Uneven access to smoke-free laws and policies and its effect on health equity in the United States: 2000–2019. American Journal of Public Health 2019;109(11):1568–75.31536405
Hagedorn J, Paras CA, Greenwich H, Hagopian A. The role of labor unions in creating working conditions that promote public health. American Journal of Public Health 2016;106(6):989–95.27077343
Hahn EJ. Smokefree legislation: a review of health and economic outcomes research. American Journal of Preventive Medicine 2010;39(6 Suppl 1):S66–S76.21074680
Hahn EJ, Rayens MK, Langley RE, Darville A, Dignan M. Time since smoke-free law and smoking cessation behaviors. Nicotine & Tobacco Research 2009;11(8):1011–5.19493908
Hair E, Pitzer L, Bennett M, Halenar M, Rath J, Cantrell J, Dorrler N, Asche E, Vallone DM. Harnessing youth and young adult culture: improving the reach and engagement of the truth® campaign. Journal of Health Communication 2017;22(7):568–75.28548610
Hair EC, Holtgrave DR, Romberg AR, Bennett M, Rath JM, Diaz MC, Vallone DM. Cost-effectiveness of using mass media to prevent tobacco use among youth and young adults: The FinishIt campaign. International Journal of Environmental Research and Public Health 2019;16(22):4312.31698724
Hale JW, Lewis C, Nazir N, Daley SM, Goeckner R, Gunville J, Faseru B, Greiner KA, Choi WS, Daley CM. One-time education sessions to help American Indian smokeless tobacco users quit. Journal of Community Health 2020;45(3):526–33.31773565
Hall J, Cho HD, Maldonado-Molina M, George TJ Jr, Shenkman EA, Salloum RG. Rural-urban disparities in tobacco retail access in the southeastern United States: CVS vs. the dollar stores. Preventive Medicine Reports 2019a;15:100935.31360628
Hall MG, Byron JM, Brewer NT, Noar SM, Ribisl KM. Interest in illicit purchase of cigarettes under a very low nicotine content product standard. Nicotine & Tobacco Research 2019b;21(Suppl 1):S128–S132.31867641
Halpern SD, French B, Small DS, Saulsgiver K, Harhay MO, Audrain-McGovern J, Loewenstein G, Brennan TA, Asch DA, Volpp KG. Randomized trial of four financial-incentive programs for smoking cessation. New England Journal of Medicine 2015;372(22):2108–17.25970009
Halpern SD, Harhay MO, Saulsgiver K, Brophy C, Troxel AB, Volpp KG. A pragmatic trial of e-cigarettes, incentives, and drugs for smoking cessation. New England Journal of Medicine 2018;378(24):2302–10.29791259
Hammig B, Daniel-Dobbs P, Blunt-Vinti H. Electronic cigarette initiation among minority youth in the United States. American Journal of Drug and Alcohol Abuse 2017;43(3):306–10.27494770
Hannon PA, Garson G, Harris JR, Hammerback K, Sopher CJ, Clegg-Thorp C. Workplace health promotion implementation, readiness, and capacity among midsize employers in low-wage industries: a national survey. Journal of Occupational and Environmental Medicine 2012a;54(11):1337–43.23090160
Hannon PA, Hammerback K, Garson G, Harris JR, Sopher CJ. Stakeholder perspectives on workplace health promotion: a qualitative study of midsized employers in low-wage industries. American Journal of Health Promotion 2012b;27(2):103–10.23113780
Hardin DF. Blowing electronic smoke: electronic cigarettes, regulation, and protecting the public health. Journal of Law, Technology & Policy 2011;Fall:433–62.
Harlow A, Stokes A, Brooks D. Socio-economic and racial/ethnic differences in e-cigarette uptake among cigarette smokers: longitudinal analysis of the Population Assessment of Tobacco and Health (PATH) study. Nicotine & Tobacco Research 2019;21(10): 1385–93.29986109
Harrington KF, Kim Y-i, Chen M, Ramachandran R, Pisu M, Sadasivam RS, Houston TK, Bailey WC. Web-based intervention for transitioning smokers from inpatient to outpatient care: an RCT. American Journal of Preventive Medicine 2016;51(4):620–9.27647062
Harris JK, Carothers BJ, Luke DA, Silmere H, McBride TD, Pion M. Exempting casinos from the Smoke-free Illinois Act will not bring patrons back: they never left. Tobacco Control 2012;21(3):373–6.21676951
Hartmann-Boyce J, Livingstone-Banks J, Ordonez-Mena JM, Fanshawe TR, Lindson N, Freeman SC, Sutton AJ, Theodoulou A, Aveyard P. Behavioural interventions for smoking cessation: an overview and network meta-analysis. Cochrane Database of Systematic Reviews 2021, Issue 1. Art. No.: CD013229. DOI: 10.1002/14651858.CD013229.pub2.
Harvard T.H. Chan School of Public Health. Life in Rural America: Part II—Experiences and Views from Rural America on Economic and Health Issues and Life in Rural Communities, 2019; <https://www.rwjf.org/en/library/research/2019/05/life-in-rural-america--part-ii.html>; accessed: July 19, 2021.
Harvey J, Chadi N, Society CP, Committee AH. Preventing smoking in children and adolescents: recommendations for practice and policy. Paediatrics & Child Health 2016;21(4):209–14.
Haskins LB, Payne CA, Schiavone WM, Beach SRH, MacKillop J, vanDellen MR. Feasibility, tolerability, and potential advantages of a dyadic financial incentive treatment for smoking cessation among dual-smoker couples: a pilot study. Experimental and Clinical Psychopharmacology 2022;30(6):1001–7.34618496
Hatsukami DK, Donny EC, Koopmeiners JS, Benowitz NL. Compensatory smoking from gradual and immediate reduction in cigarette nicotine content. Cancer Epidemiology, Biomarkers & Prevention 2015;24(2):472–6.
Hatsukami DK, Luo X, Jensen JA, al’Absi M, Allen SS, Carmella SG, Chen M, Cinciripini PM, Denlinger-Apte R, Drobes DJ, . Effect of Immediate vs Gradual Reduction in Nicotine Content of Cigarettes on Biomarkers of Smoke Exposure: A Randomized Clinical Trial. JAMA: the Journal of the American Medical Association 2018;320(9):880–91.30193275
Hatzenbuehler ML, Keyes KM, Hamilton A, Hasin DS. State-level tobacco environments and sexual orientation disparities in tobacco use and dependence in the USA. Tobacco Control 2014;23(E2):e127–e32.24570099
Hawaii State Legislature. A bill for an act relating to health. Be it enacted by the legislature of The State of Hawaii (HB No. 1895), 2018; <https://www.capitol.hawaii.gov/sessions/session2018/bills/HB1895_CD1_.htm>; accessed: April 23, 2020.
Hawkins SS, Bach N, Baum CF. Impact of tobacco control policies on adolescent smoking. Journal of Adolescent Health 2016;58(6):679–85.
Hawkins SS, Cohen BB. Affordable Care Act standards for race and ethnicity mask disparities in maternal smoking during pregnancy. Preventive Medicine 2014;65:92–5.24823903
HealthIT.gov. Meaningful use: meaningful use and the shift to the merit-based incentive payment system, October 22, 2019; <https://www.healthit.gov/topic/meaningful-use-and-macra/meaningful-use>; accessed: February 27, 2024.
Hearod JB, Wetherill MS, Salvatore AL, Jernigan VBB. Community-based participatory intervention research with American Indian communities: what is the state of the science? Current Developments in Nutrition 2019;3(Suppl 2):39–52.31453427
Hebert KK, Cummins SE, Hernandez S, Tedeschi GJ, Zhu S-H. Current major depression among smokers using a state quitline. American Journal of Preventive Medicine 2011;40(1):47–53.21146767
Heffner JL, Mull KE, Watson NL, McClure JB, Bricker JB. Long-term smoking cessation outcomes for sexual minority versus nonminority smokers in a larger randomized controlled trial of two web-based interventions. Nicotine & Tobacco Research 2020;22(9):1596–604.31290550
Henderson BJ, Wall TR, Henley BM, Kim CH, McKinney S, Lester HA. Menthol enhances nicotine reward-related behavior by potentiating nicotine-induced changes in nAChR function, nAChR upregulation, and DA neuron excitability. Neuropsychopharmacology 2017;42(12):2285–91.28401925
Hendricks PS, Westmaas JL, Ta Park VM, Thorne CB, Wood SB, Baker MR, Lawler RM, Webb Hooper M, Delucchi KL, Hall SM. Smoking abstinence-related expectancies among American Indians, African Americans, and women: potential mechanisms of tobacco-related disparities. Psychology of Addictive Behaviors 2014;28(1):193–205.23528192
Henriksen L, Feighery EC, Schleicher NC, Cowling DW, Kline RS, Fortmann SP. Is adolescent smoking related to the density and proximity of tobacco outlets and retail cigarette advertising near schools? Preventive Medicine 2008;47(2):210–4.18544462
Henriksen L, Schleicher NC, Barker DC, Liu Y, Chaloupka FJ. Prices for tobacco and nontobacco products in pharmacies versus other stores: results from retail marketing surveillance in California and in the United States. American Journal of Public Health 2016;106(10):1858–64.27552272
Henriksen L, Schleicher NC, Johnson TO, Roeseler A, Zhu S-H. Retail tobacco marketing in rural versus nonrural counties: product availability, discounts, and prices. Health Promotion Practice 2020;21 (1 Suppl):27S–36S.31908200
Heron M. Deaths: leading causes for 2010. National Vital Statistics Reports 2013;62(6):1–96.
Hersch J. Gender, income levels, and the demand for cigarettes. Journal of Risk and Uncertainty 2000;21(2–3):263–82.
HITECH Act, Public Law 111-5, U.S. Statutes at Large 123 (February 17, 2009):226.
Higgins ST, DeSarno M, Bunn JY, Gaalema DE, Leventhal AM, Davis DR, Streck JM, Harfmann RF, Markesich C, Orr E, . Cumulative vulnerabilities as a potential moderator of response to reduced nicotine content cigarettes. Preventive Medicine 2021;152(Pt 2):106714.34242666
Higgins ST, Erath TG, DeSarno M, Reed DD, Gaalema DE, Sigmon SC, Heil SH, Tidey JW. Leveraging the cigarette purchase task to understand relationships between cumulative vulnerabilities, the relative reinforcing effects of smoking, and response to reduced nicotine content cigarettes. Preventive Medicine 2022a;165(Pt B):107206.35995102
Higgins ST, Nighbor TD, Kurti AN, Heil SH, Slade EP, Shepard DS, Solomon LJ, Lynch ME, Johnson HK, Markesich C, . Randomized controlled trial examining the efficacy of adding financial incentives to best practices for smoking cessation among pregnant and newly postpartum women. Preventive Medicine 2022b;165(Pt B):107012.35248683
Higgins ST, Tidey JW, Sigmon SC, Heil SH, Gaalema DE, Lee D, Hughes JR, Villanti AC, Bunn JY, Davis DR, . Changes in cigarette consumption with reduced nicotine content cigarettes among smokers with psychiatric conditions or socioeconomic disadvantage: 3 randomized clinical trials. JAMA Network Open 2020;3(10):e2019311.33079196
Hill S, Amos A, Clifford D, Platt S. Impact of tobacco control interventions on socioeconomic inequalities in smoking: review of the evidence. Tobacco Control 2014;23(e2):e89–e97.24046211
Hirschtick JL, Mattingly DT, Cho B, Arciniega LZ, Levy DT, Sanchez-Romero LM, Jeon J, Land SR, Mistry R, Meza R, . Exclusive, dual, and polytobacco use among U.S. adults by sociodemographic factors: results from 3 nationally representative surveys. American Journal of Health Promotion 2021;35(3):377–87.33047619
Hollar TL, Cook N, Quinn D, Phillips T, DeLucca M. Smokefree multi-unit housing policies show promise in reducing secondhand smoke exposure among racially and ethnically diverse, low-income seniors. Journal of Immigrant and Minority Health 2017;19(6):1281–9.27189486
Hollis JF, McAfee TA, Fellows JL, Zbikowski SM, Stark M, Riedlinger K. The effectiveness and cost effectiveness of telephone counselling and the nicotine patch in a state tobacco quitline. Tobacco Control 2007;16 (Suppl 1):I53–I59.18048633
Holm AL, Davis RM. Clearing the airways: advocacy and regulation for smoke-free airlines. Tobacco Control 2004;13(Suppl 1)i30–i36.14985614
Holmes CB, King BA, Babb SD. Stuck in neutral: stalled progress in statewide comprehensive smoke-free laws and cigarette excise taxes, United States, 2000–2014. Preventing Chronic Disease 2016;13:E80.27309417
Homa DM, Neff LJ, King BA, Caraballo RS, Bunnell RE, Babb SD, Garrett BE, Sosnoff CS, Wang L. Vital signs: disparities in nonsmokers’ exposure to secondhand smoke—United States, 1999–2012. Morbidity and Mortality Weekly Report 2015;64(4):103–8.25654612
Hori M, Tanaka H, Wakai K, Sasazuki S, Katanoda K. Secondhand smoke exposure and risk of lung cancer in Japan: a systematic review and meta-analysis of epidemiologic studies. Japanese Journal of Clinical Oncology 2016;46(10):942–51.27511987
Horn K, Dearfield CT, Johnson SB, Krost K, Rincon Gallardo Patino S, Gray T, Crandell I, Bernat DH. Smoking cessation intentions and attempts one year after the federally mandated smoke-free housing rule. Preventive Medicine Reports 2021;24:101600.34976657
Houle B, Siegel M. Smoker-free workplace policies: developing a model of public health consequences of workplace policies barring employment to smokers. Tobacco Control 2009;18(1):64–9.19168490
Huang J, Gwarnicki C, Xu X, Caraballo RS, Wada R, Chaloupka FJ. A comprehensive examination of own- and cross-price elasticities of tobacco and nicotine replacement products in the U.S. Preventive Medicine 2018.
Huang J, King BA, Babb SD, Xu X, Hallett C, Hopkins M. Sociodemographic disparities in local smoke-free law coverage in 10 states. American Journal of Public Health 2015;105(9):1806–13.26180972
Huang LL, Baker HM, Meernik C, Ranney LM, Richardson A, Goldstein AO. Impact of non-menthol flavours in tobacco products on perceptions and use among youth, young adults and adults: a systematic review. Tobacco Control 2017a;26(6):709–19.27872344
Huang LL, Lazard AJ, Pepper JK, Noar SM, Ranney LM, Goldstein AO. Impact of the real cost campaign on adolescents’ recall, attitudes, and risk perceptions about tobacco use: a national study. International Journal of Environmental Research and Public Health 2017b;14(1).
Hudmon KS, Fenlon CM, Corelli RL, Prokhorov AV, Schroeder SA. Tobacco sales in pharmacies: time to quit. Tobacco Control 2006;15(1):35–8.16436403
Hunt MK, Lederman R, Stoddard AM, LaMontagne AD, McLellan D, Combe C, Barbeau E, Sorensen G. Process evaluation of an integrated health promotion/occupational health model in WellWorks-2. Health Education & Behavior 2005;32(1):10–26.15642751
Hurt RD, Berge KG, Offord KP, Leonard DA, Gerlach DK, Renquist CL, O’Hara MR. The making of a smoke-free medical center. JAMA: the Journal of the American Medical Association 1989;261(1):95–7.2909002
Hyland A, Barnoya J, Corral JE. Smoke-free air policies: past, present and future. Tobacco Control 2012;21(2):154–61.22345239
Hyland A, Higbee C, Travers MJ, Van Deusen A, Bansal-Travers M, King B, Cummings KM. Smoke-free homes and smoking cessation and relapse in a longitudinal population of adults. Nicotine & Tobacco Research 2009;11(6):614–8.19346505
Hymel PA, Loeppke RR, Baase CM, Burton WN, Hartenbaum NP, Hudson TW, McLellan RK, Mueller KL, Roberts MA, Yarborough CM, . Workplace health protection and promotion: a new pathway for a healthier—and safer—workforce. Journal of Occupational and Environmental Medicine 2011;53(6):695–702.21654443
Hymowitz N, Mouton C, Edkholdt H. Menthol cigarette smoking in African Americans and Whites. Tobacco Control 1995;4(2):194–5.
Ickes MJ, Hahn EJ, McCann M, Kercsmar S. Tobacco-free Take Action!: Increasing policy adherence on a college campus. World Medical Health Policy 2013;5(1):47–56.23936747
Ickes MJ, Rayens MK, Wiggins AT, Hahn EJ. A tobacco-free campus ambassador program and policy compliance. Journal of American College Health 2015;63(2):126–33.25612060
Independents Gas & Service Stations Associations Inc. v. City of Chicago, 112 F. Supp. 3d 749 (N.D. Ill. 2015).
Institute of Medicine. Unequal Treatment: Confronting Racial and Ethnic Disparities in Health Care. Washington (DC): The National Academies Press, 2003.
Institute of Medicine. Examining the Health Disparities Research Plan of the National Institutes of Health: Unfinished Business. Washington (DC): The National Academies Press, 2006.
Institute of Medicine. Ending the Tobacco Problem: A Blueprint for the Nation. Washington (DC): The National Academies Press, 2007.
Institute of Medicine. Secondhand Smoke Exposure and Cardiovascular Effects: Making Sense of the Evidence. Washington (DC): The National Academies Press, 2010.
Institute of Medicine. For the Public’s Health: The Role of Measurement in Action and Accountability. Washington (DC): The National Academies Press, 2011.
Institute of Medicine. Public Health Implications of Raising the Minimum Age of Legal Access to Tobacco Products. Washington (DC): The National Academies Press, 2015.
Institute of Medicine, Committee to Assess Worksite Preventive Health Program Needs for NASA Employees and Food and Nutrition Board. Integrating Employee Health: A Model Program for NASA. Washington (DC): The National Academies Press, 2005.
International Agency for Research on Cancer and World Health Organization. Evaluating the Effectiveness of Smoke-free Policies. IARC Handbooks of Cancer Prevention, Tobacco Control, Vol. 13. Lyon (France): International Agency for Research on Cancer, 2009.
International Agency for Research on Cancer and World Health Organization. Effectiveness of Tax and Price Policies for Tobacco Control. IARC Handbooks of Cancer Prevention, Tobacco Control, Vol. 14. Lyon (France): International Agency for Research on Cancer, 2011.
International Association for Worksite Health Promotion. IAWHP’s Las Vegas Announcement on Worksite Health, 2012; <http://www.acsm-iawhp.org/files/public/Las%20Vegas%20Announcement%20on%20Worksite%20Health%20Promotion%202012_Final.pdf>; accessed: April 17, 2020.^*^
International Collaboration for Participatory Health Research. Position Paper No. 1: What Is Participatory Health Research. Berlin (Germany): International Collaboration for Participatory Health Research, 2013.
International Labour Office. Guidelines on Occupational Safety and Health Management Systems: ILO-OSH 2001, 2001; <http://www.ilo.org/public/libdoc/ilo/2001/101B09_287_engl.pdf>; accessed: April 17, 2020.
Isenberg JY, Quinones AR, Slatore CG, Bryson WC, Thielke SM. Trends in cigarette smoking and cessation among Medicare managed care recipients, 2005–2012. Addictive Behaviors 2016;58:155–60.26946446
Israel BA, Schulz AJ, Parker EA, Becker AB. Community-based participatory research: policy recommendations for promoting a partnership approach in health research. Education for Health 2001;14(2):182–97.14742017
Israel BA, Schulz AJ, Parker EA, Becker AB, Allen AJ 3rd, Guzman JR. Critical issues in developing and following community-based participatory research principles. In: Minkler M, Wallerstein N, editors. Community-Based Participatory Research for Health. San Francisco: Jossey-Bass, 2003.
Issabakhsh M, Meza R, Li Y, Yuan Z, Sanchez-Romero LM, Levy DT. Public health impact of a U.S. menthol cigarette ban on the non-Hispanic black population: a simulation study. Tobacco Control 2022.
Jemal A, Lin CC, Davidoff AJ, Han X. Changes in insurance coverage and stage at diagnosis among nonelderly patients with cancer after the Affordable Care Act. Journal of Clinical Oncology 2017;35(35):3906–15.28885865
Jiang R-T, Cheng K-C, Acevedo-Bolton V, Klepeis NE, Repace JL, Ott WR, Hildemann LM. Measurement of fine particles and smoking activity in a statewide survey of 36 California Indian casinos. Journal of Exposure Science & Environmental Epidemiology 2011;21(1):31–41.20160761
Jin Y, Lu B, Berman M, Klein EG, Foraker RE, Ferketich AK. The impact of tobacco-free pharmacy policies on smoking prevalence. Journal of the American Pharmacists Association 2016a;56(6):627–32.27667500
Jin Y, Lu B, Klein EG, Berman M, Foraker RE, Ferketich AK. Tobacco-free pharmacy laws and trends in tobacco retailer density in California and Massachusetts. American Journal of Public Health 2016b;106(4):679–85.26890173
Jones JW, Novick WM, Sade RM. Should a medical center deny employment to a physician because he smokes tobacco products? Annals of Thoracic Surgery 2014;98(3):799–805.25193184
Jorde LB, Wooding SP. Genetic variation, classification and ‘race’. Nature Genetics 2004;36(11 Suppl):S28–S33.15508000
Joseph AM, Arikian NJ, An LC, Nugent SM, Sloan RJ, Pieper CF, Group GR. Results of a randomized controlled trial of intervention to implement smoking guidelines in Veterans Affairs medical centers: increased use of medications without cessation benefit. Medical Care 2004;42(11):1100–10.15586837
Journal of the American Pharmacists Association. Report of the 2015 APhA House of Delegates. Journal of the American Pharmacists Association 2015;55(4):364–75.26161480
Kalkhoran S, Lisha NE, Neilands TB, Jordan JW, Ling PM. Evaluation of bar and nightclub intervention to decrease young adult smoking in New Mexico. Journal of Adolescent Health 2016;59(2):222–9.
Kandra KL, McCullough A, Summerlin-Long S, Agans R, Ranney L, Goldstein AO. The evaluation of North Carolina’s state-sponsored youth tobacco prevention media campaign. Health Education Research 2013;28(1):1–14.22907537
Kang JY, Kenemer B, Mahoney M, Tynan MA. State preemption: impacts on advances in tobacco control. Journal of Public Health Management and Practice 2020;26(Suppl 2):S54–S61.32004223
Kaper J, Wagena EJ, Willemsen MC, van Schayck CP. Reimbursement for smoking cessation treatment may double the abstinence rate: results of a randomized trial. Addiction 2005;100(7):1012–20.15955017
Kaplan CM, Graetz I, Waters TM. Most exchange plans charge lower tobacco surcharges than allowed, but many tobacco users lack affordable coverage. Health Affairs 2014;33(8):1466–73.25092850
Karn S, Fernandez A, Grossberg LA, Robertson T, Sharp B, Huang P, Loukas A. Systematically improving tobacco cessation patient services through electronic medical record integration. Health Promotion Practice 2016;17(4):482–9.27199147
Kaslow AA, Romano PS, Schwarz E, Shaikh U, Tong EK. Building and scaling-up California Quits: supporting health systems change for tobacco treatment. American Journal of Preventive Medicine 2018;55 (6 Suppl 2):S214–S221.30454676
Kauffman RM, Ferketich AK, Wewers ME. Tobacco policy in American prisons, 2007. Tobacco Control 2008;17(5):357–60.18603604
Kegler MC, Bundy L, Haardorfer R, Escoffery C, Berg C, Yembra D, Kreuter M, Hovell M, Williams R, Mullen PD, . A minimal intervention to promote smoke-free homes among 2-1-1 callers: a randomized controlled trial. American Journal of Public Health 2015;105(3):530–7.25602863
Kegler MC, Haardorfer R, Bundy LT, Escoffery C, Williams RS, Hovell M, Kreuter M, Mullen PD. Moderators of establishing a smoke-free home: pooled data from three randomized controlled trials of a brief intervention. Journal of Community Health 2019;44(1):121–6.30101386
Kelder SH, Mantey DS, Van Dusen D, Case K, Haas A, Springer AE. A middle school program to prevent e-cigarette use: a pilot study of “CATCH My Breath”. Public Health Reports 2020;135(2):220–9.31968177
Keller PA, Feltracco A, Bailey LA, Li Z, Niederdeppe J, Baker TB, Fiore MC. Changes in tobacco quitlines in the United States, 2005–2006. Preventing Chronic Disease 2010;7(2):A36.20158964
Keller PA, Schillo BA, Kerr AN, Lien RK, Saul J, Dreher M, Lachter RB. Increasing reach by offering choices: results from an innovative model for statewide services for smoking cessation. Preventive Medicine 2016;91:96–102.27514248
Kennedy RD, Awopegba A, De Leon E, Cohen JE. Global approaches to regulating electronic cigarettes. Tobacco Control 2017;26(4):440–5.27903958
Kennedy SM, Davis SP, Thorne SL. Smoke-free policies in U.S. prisons and jails: a review of the literature. Nicotine & Tobacco Research 2015;17(6):629–35.25475088
Kidd JD, Paschen-Wolff MM, Mericle AA, Caceres BA, Drabble LA, Hughes TL. A scoping review of alcohol, tobacco, and other drug use treatment interventions for sexual and gender minority populations. Journal of Substance Abuse Treatment 2022;133:108539.34175174
Kim A, Hansen H, Duke J, Davis K, Alexander R, Rowland A, Mitchko J. Does digital ad exposure influence information-seeking behavior online? Evidence from the 2012 Tips From Former Smokers National Tobacco Prevention Campaign. Journal of Medical Internet Research 2016a;18(3):e64.26983849
Kim AE, Nonnemaker JM, Loomis BR, Baig A, Hill E, Holloway JW, Farrelly MC, Shafer PR. Influence of tobacco displays and ads on youth: a virtual store experiment. Pediatrics 2013;131(1):e88–e95.23209108
Kim AE, Nonnemaker JM, Loomis BR, Shafer PR, Shaikh A, Hill E, Holloway JW, Farrelly MC. Influence of point-of-sale tobacco displays and graphic health warning signs on adults: evidence from a virtual store experimental study. American Journal of Public Health 2014;104(5):888–95.24625149
Kim M, Shi R, Cappella JN. Effect of character-audience similarity on the perceived effectiveness of anti-smoking PSAs via engagement. Health Communication 2016b; 31(10):1193–204.26891148
Kim SS. A culturally adapted smoking cessation intervention for Korean Americans: preliminary findings. Journal of Transcultural Nursing 2017;28(1):24–31.26289318
Kim SS, Kim SH, Fang H, Kwon S, Shelley D, Ziedonis D. A culturally adapted smoking cessation intervention for Korean Americans: a mediating effect of perceived family norm toward quitting. Journal of Immigrant and Minority Health 2015;17(4):1120–9.24878686
King BA, Babb SD, Tynan MA, Gerzoff RB. National and state estimates of secondhand smoke infiltration among U.S. multiunit housing residents. Nicotine & Tobacco Research 2013a;15(7):1316–21.23248030
King BA, Dube SR, Homa DM. Smoke-free rules and secondhand smoke exposure in homes and vehicles among U.S. adults, 2009–2010. Preventing Chronic Disease 2013b;10:E79.23680508
Kingsbury JH, Reckinger D. Clearing the air: smoke-free housing policies, smoking, and secondhand smoke exposure among affordable housing residents in Minnesota, 2014–2015. Preventing Chronic Disease 2016;13:E111.27536903
Kingsley M, McGinnes H, Song G, Doane J, Henley P. Impact of Massachusetts’ statewide sales restriction on flavored and menthol tobacco products on tobacco sales in Massachusetts and surrounding states, June 2020. American Journal of Public Health 2022;112(8):1147–50.35830660
Kingsley M, Setodji CM, Pane JD, Shadel WG, Song G, Robertson J, Kephart L, Henley P, Sanouri Ursprung WW. Short-term impact of a flavored tobacco restriction: changes in youth tobacco use in a Massachusetts community. American Journal of Preventive Medicine 2019;57(6):741–8.31668668
Kingsley M, Setodji CM, Pane JD, Shadel WG, Song G, Robertson J, Kephart L, Zepeda S, Henley P, Ursprung WWS. Longer-term impact of the flavored tobacco restriction in two Massachusetts communities: a mixed-methods study. Nicotine & Tobacco Research 2021;23(11):1928–35.34228120
Kirchner TR, Cantrell J, Anesetti-Rothermel A, Ganz O, Vallone DM, Abrams DB. Geospatial exposure to point-of-sale tobacco: real-time craving and smoking-cessation outcomes. American Journal of Preventive Medicine 2013;45(4):379–85.24050412
Klassen AC, Lee NL, Pankiewicz A, Ward R, Shuster M, Ogbenna BT, Wade A, Boamah M, Osayameh O, Rule AM, . Secondhand smoke exposure and smoke-free policy in Philadelphia public housing. Tobacco Regulatory Science 2017;3(2):192–203.28944277
Klepeis NE, Dhaliwal N, Hayward G, Acevedo-Bolton V, Ott WR, Read N, Layton S, Jiang R, Cheng KC, Hildemann LM, . Measuring indoor air quality and engaging California Indian stakeholders at the Win-River Resort and Casino: collaborative smoke-free policy development. International Journal of Environmental Research and Public Health 2016;13(1):143.26805860
Klepeis NE, Omoto J, Ong SL, Omoto HS, Dhaliwal N. Small proportions of actively-smoking patrons and high PM2.5 levels in southern California tribal casinos: support for smoking bans or designated smoking areas. BMC Public Health 2012;12:819.22998850
Kochanek KD, Murphy SL, Xu J, Tejada-Vera B. Deaths: final data for 2014. National Vital Statistics Reports 2016;65(4):1–122.
Kock L, Brown J, Hiscock R, Tattan-Birch H, Smith C, Shahab L. Individual-level behavioural smoking cessation interventions tailored for disadvantaged socioeconomic position: a systematic review and meta-regression. Lancet Public Health 2019;4(12):e628–e644.31812239
Koma JW, Donohue JM, Barry CL, Huskamp HA, Jarlenski M. Medicaid coverage expansions and cigarette smoking cessation among low-income adults. Medical Care 2017;55(12):1023–9.29068908
Komro KA, Livingston MD, Markowitz S, Wagenaar AC. The effect of an increased minimum wage on infant mortality and birth weight. American Journal of Public Health 2016;106(8):1514–6.27310355
Kong AY, Delamater PL, Gottfredson NC, Ribisl KM, Baggett CD, Golden SD. Sociodemographic inequities in tobacco retailer density: do neighboring places matter? Health & Place 2021;71:102653.34461529
Kong AY, Delamater PL, Gottfredson NC, Ribisl KM, Baggett CD, Golden SD. Neighborhood inequities in tobacco retailer density and the presence of tobacco-selling pharmacies and tobacco shops. Health Education & Behavior 2022;49(3):478–87.33870767
Kong AY, King BA. Boosting the tobacco control vaccine: recognizing the role of the retail environment in addressing tobacco use and disparities. Tobacco Control 2021;30(e2):e162–e168.32967986
Kool USA. Kool Business Review 2002 Market: USA. 2002.
Kool USA. Kool Business Review 2003 Market: USA. 2003.
Kosmider L, Sobczak A, Fik M, Knysak J, Zaciera M, Kurek J, Goniewicz ML. Carbonyl compounds in electronic cigarette vapors: effects of nicotine solvent and battery output voltage. Nicotine & Tobacco Research 2014;16(10):1319–26.24832759
Kowitt SD, Lazard AJ, Queen TL, Noar SM, Goldstein AO. Adolescents’ aided recall of targeted and non-targeted tobacco communication campaigns in the United States. International Journal of Environmental Research and Public Health 2018;15(11):2363.30366436
Kowitt SD, Meernik C, Baker HM, Osman A, Huang LL, Goldstein AO. Perceptions and experiences with flavored non-menthol tobacco products: a systematic review of qualitative studies. International Journal of Environmental Research and Public Health 2017;14(4):338.28333107
Krebs NM, Zhu J, Wasserman E, Kuprewicz R, Martinez DJ, Veldheer S, Livelsberger C, Modesto J, Reinhart L, Trushin N, . Switching to progressively reduced nicotine content cigarettes in smokers with low socioeconomic status: a double-blind randomized clinical trial. Nicotine & Tobacco Research 2021;23(6):992–1001.33249498
Kristman-Valente AN, Flaherty BP. Latino cigarette smoking patterns by gender in a U.S.-national sample. Annals of Behavioral Medicine 2016;50(1):34–47.26304857
Kruger J, Jama A, Homa DM, Babb SD, King BA. Smokefree home and vehicle rules by tobacco use status among U.S. adults. Preventive Medicine 2015;78:9–13.26092055
Kruse GR, Kelley JH, Linder JA, Park ER, Rigotti NA. Implementation of an electronic health record-based care management system to improve tobacco treatment. Journal of General Internal Medicine 2012;27(12):1690–6.22865018
Ku L, Brantley E, Bysshe T, Steinmetz E, Bruen BK. How Medicaid and other public policies affect use of tobacco cessation therapy, United States, 2010–2014. Preventing Chronic Disease 2016;13:E150.27788063
Kyriakos CN, Driezen P, Fong G, Chung-Hall J, Hyland A, Geboers C, Quah ACK, Willemsen MC, Filippidis FT. Impact of the European Union’s menthol cigarette ban on smoking cessation outcomes: longitudinal findings from the 2020–2021 ITC Netherlands Surveys. Tobacco Control 2022.
LaChance H, Cioe PA, Tooley E, Colby SM, O’Farrell TJ, Kahler CW. Behavioral couples therapy for smoking cessation: a pilot randomized clinical trial. Psychology of Addictive Behaviors 2015;29(3):643–52.25642582
Ladapo JA, Tseng C-H, Sherman SE. Financial incentives for smoking cessation in hospitalized patients: a randomized clinical trial. American Journal of Medicine 2020;133(6):741–9.31982494
Land T, Warner D, Paskowsky M, Cammaerts A, Wetherell L, Kaufmann R, Zhang L, Malarcher A, Pechacek T, Keithly L. Medicaid coverage for tobacco dependence treatments in Massachusetts and associated decreases in smoking prevalence. PLoS One 2010;5(3):e9770.20305787
Landman A, Ling PM, Glantz SA. Tobacco industry youth smoking prevention programs: protecting the industry and hurting tobacco control. American Journal of Public Health 2002;92(6):917–30.12036777
Lawman HG, Henry KA, Scheeres A, Hillengas A, Coffman R, Strasser AA. Tobacco retail licensing and density 3 years after license regulations in Philadelphia, Pennsylvania (2012–2019). American Journal of Public Health 2020;110(4):547–53.32078358
Lawn S, Pols R. Smoking bans in psychiatric inpatient settings? A review of the research. Australian and New Zealand Journal of Psychiatry 2005;39(10):866–85.16168014
Le TT, Mendez D. An estimation of the harm of menthol cigarettes in the United States from 1980 to 2018. Tobacco Control 2021.
Leatherdale ST, Strath JM. Tobacco retailer density surrounding schools and cigarette access behaviors among underage smoking students. Annals of Behavioral Medicine 2007;33(1):105–11.17291176
Lee H, Hodgkin D, Johnson MP, Porell FW. Medicaid expansion and racial and ethnic disparities in access to health care: applying the National Academy of Medicine definition of health care disparities. Inquiry 2021;58:46958021991293.33565343
Lee JG, Henriksen L, Rose SW, Moreland-Russell S, Ribisl KM. A systematic review of neighborhood disparities in point-of-sale tobacco marketing. American Journal of Public Health 2015;10(5)9:e8–e18.
Lee JG, Matthews AK, McCullen CA, Melvin CL. Promotion of tobacco use cessation for lesbian, gay, bisexual, and transgender people: a systematic review. American Journal of Preventive Medicine 2014;47(6):823–31.25455123
Lee JG, Sun DL, Schleicher NM, Ribisl KM, Luke DA, Henriksen L. Inequalities in tobacco outlet density by race, ethnicity and socioeconomic status, 2012, USA: results from the ASPiRE Study. Journal of Epidemiology and Community Health 2017;71(5):487–92.28249990
Lee JGL, Kong AY, Sewell KB, Golden SD, Combs TB, Ribisl KM, Henriksen L. Associations of tobacco retailer density and proximity with adult tobacco use behaviours and health outcomes: a meta-analysis. Tobacco Control 2022;31(e2):e189–e200.34479990
Lee JGL, Orlan EN, Sewell KB, Ribisl KM. A new form of nicotine retailers: a systematic review of the sales and marketing practices of vape shops. Tobacco Control 2018a;27(e1):e70–e75.29208738
Lee JGL, Schleicher NC, Leas EC, Henriksen L. U.S. Food and Drug Administration inspection of tobacco sales to minors at top pharmacies, 2012–2017. JAMA Pediatrics 2018b;172(11):1089–90.30193340
Leeks KD, Hopkins DP, Soler RE, Aten A, Chattopadhyay SK. Worksite-Based Incentives and Competitions to Reduce Tobacco Use: A Systematic Review, 2010; <https://www.thecommunityguide.org/media/pdf/tobac-ajpm-evrev-incentives.pdf>; accessed: June 19, 2023.
Leffert N, Benson PL, Scales PC, Sharma AR, Drake DR, Blyth DA. Developmental assets: measurement and prediction of risk behaviors among adolescents. Applied Developmental Science 1998;2(4):209–30.
Legault M, Pasternak DB. Can an employer implement a nicotine-free hiring policy?—It depends on state law (U.S.), January 8, 2020; <https://www.natlawreview.com/article/can-employer-implement-nicotine-free-hiring-policy-it-depends-state-law-us>; accessed: July 13, 2022.
Lemaire RH, Bailey L, Leischow SJ. Meeting the tobacco cessation coverage requirement of the Patient Protection and Affordable Care Act: state smoking cessation quitlines and cost sharing. American Journal of Public Health 2015;105(Suppl 5):S699–S705.26447918
Lemhoefer C, Rabe GL, Wellmann J, Bernstein SL, Cheung KW, McCarthy WJ, Lauridsen SV, Spies C, Neuner B. Emergency department-initiated tobacco control: update of a systematic review and meta-analysis of randomized controlled trials. Preventing Chronic Disease 2017;14:E89.28981403
Lempert LK, Grana R, Glantz SA. The importance of product definitions in U.S. e-cigarette laws and regulations. Tobacco Control 2016;25(e1):e44–e51.25512432
Lenhart O. The impact of minimum wages on population health: evidence from 24 OECD countries. European Journal of Health Economics 2017;18(8):1031–9.
Lenk K, Rode P, Fabian L, Bernat D, Klein E, Forster J. Cigarette use among young adults: comparisons between 2-year college students, 4-year college students, and those not in college. Journal of American College Health 2012;60(4):303–8.22559089
Leung-Gagné M, McCombs J, Scott C, Losen D. Pushed Out: Trends and Disparities in Out-of-School Suspension, September 2022; <https://learningpolicyinstitute.org/media/3885/download?inline&file=CRDC_School_Suspension_REPORT.pdf>; accessed: August 17, 2023.
Levenstein C, Delaurier GF, Ahmed S, Balbach ED. Labor and the tobacco institute’s labor management committee in New York State: the rise and fall of a political coalition. New Solutions: A Journal of Environmental and Occupational Health Policy 2005;15(2):135–52.
Levy DE, Adamkiewicz G, Rigotti NA, Fang SC, Winickoff JP. Changes in tobacco smoke exposure following the institution of a smoke-free policy in the Boston Housing Authority. PLoS One 2015;10(9):e0137740.26360258
Levy DT, Meza R, Yuan Z, Li Y, Cadham C, Sanchez-Romero LM, Travis N, Knoll M, Liber AC, Mistry R, . Public health impact of a U.S. ban on menthol in cigarettes and cigars: a simulation study. Tobacco Control 2023;32(e1):e37–e44.34475258
Levy DT, Mumford EA, Compton C. Tobacco control policies and smoking in a population of low education women, 1992-2002. Journal of Epidemiology and Community Health 2006;60(Suppl 2):20–26.
Levy DT, Pearson JL, Villanti AC, Blackman K, Vallone DM, Niaura RS, Abrams DB. Modeling the future effects of a menthol ban on smoking prevalence and smoking-attributable deaths in the United States. American Journal of Public Health 2011;101(7):1236–40.21566034
Lewin K. Action research and minority problems. In: Lewin GW, editor. Resolving Social Conflicts: Selected Papers on Group Dynamics. New York (NY): Harper & Row, 1948:201–20.
Li L, Lin Y, Xia T, Zhu Y. Effects of electronic cigarettes on indoor air quality and health. Annual Review of Public Health 2020;41:363–80.
Lichtenstein E, Glasgow RE, Lando HA, Ossip-Klein DJ, Boles SM. Telephone counseling for smoking cessation: rationales and meta-analytic review of evidence. Health Education Research 1996;11(2):243–57.10163409
Lienemann BA, Cummins SE, Tedeschi GJ, Wong S, Zhu S-H. American Indian/Alaska Native smokers’ utilization of a statewide tobacco quitline: engagement and quitting behaviors from 2008 to 2018. Nicotine & Tobacco Research 2021;23(1):219–26.31711234
Lin W, Hobkirk AL, Zhu J, Krebs NM, Hayes JE, Richie JP Jr, Liao J, Horn K, Foulds J, Muscat JE. Effect of menthol on nicotine reduction: pooled results from two double-blind randomized controlled trials. Brain Research Bulletin 2022;189:131–8.36038015
Ling PM, Lee YO, Hong J, Neilands TB, Jordan JW, Glantz SA. Social branding to decrease smoking among young adults in bars. American Journal of Public Health 2014;104(4):751–60.24524502
Liu J, Halpern-Felsher B. The Juul curriculum is not the jewel of tobacco prevention education. Journal of Adolescent Health 2018;63(5):527–8.
Liu JJ, Wabnitz C, Davidson E, Bhopal RS, White M, Johnson MR, Netto G, Sheikh A. Smoking cessation interventions for ethnic minority groups—a systematic review of adapted interventions. Preventive Medicine 2013;57(6):765–75.24076130
Livingston CJ, Bartelmann SE, Goff NM, Aird KG. Reducing tobacco use in Oregon through multisector collaboration: aligning Medicaid and public health programs. Preventing Chronic Disease 2020;17:E155.33301393
Lopipero P, Bero LA. Tobacco interests or the public interest: 20 years of industry strategies to undermine airline smoking restrictions. Tobacco Control 2006;15(4):323–32.16885582
Loureiro SF, Pulvers K, Gosdin MM, Clift K, Rice M, Tong EK. The development of a web-based tobacco tracker tool to crowdsource campus environmental reports for smoke and tobacco-free college policies: mixed methods study. Journal of Medical Internet Research 2021;23(10):e26280.34714248
Lowry R, Johns MM, Robin LE, Kann LK. Social stress and substance use disparities by sexual orientation among high school students. American Journal of Preventive Medicine 2017;53(4):547–58.28826950
Luke DA, Hammond RA, Combs T, Sorg A, Kasman M, Mack-Crane A, Ribisl KM, Henriksen L. Tobacco town: computational modeling of policy options to reduce tobacco retailer density. American Journal of Public Health 2017;107(5):740–6.28398792
Luke DA, Sorg AA, Combs T, Robichaux CB, Moreland-Russell S, Ribisl KM, Henriksen L. Tobacco retail policy landscape: a longitudinal survey of U.S. states. Tobacco Control 2016;25(Suppl 1):i44–i51.27697947
Lukowski AV, Morris CD, Young SE, Tinkelman D. Quitline outcomes for smokers in 6 states: rates of successful quitting vary by mental health status. Nicotine & Tobacco Research 2015;17(8):924–30.26180216
Lukowski AV, Young SE, Morris CD, Tinkelman D. Characteristics of American Indian/Alaskan Native quitline callers across 14 states. Nicotine & Tobacco Research 2016;18(11):2124–9.27613942
Lupton JR, Townsend JL. A systematic review and meta-analysis of the acceptability and effectiveness of university smoke-free policies. Journal of American College Health 2015;63(4):238–47.25692536
Ma GX, Fleisher L, Gonzalez E, Edwards RL. Improving cancer awareness among Asian Americans using targeted and culturally appropriate media: a case study. Home Health Care Management & Practice 2004;17(1):39–44.
Macacu A, Autier P, Boniol M, Boyle P. Active and passive smoking and risk of breast cancer: a meta-analysis. Breast Cancer Research and Treatment 2015;154(2):213–24.26546245
Maciosek MV, Armour BS, Babb SD, Dehmer SP, Grossman ES, Homa DM, LaFrance AB, Rodes R, Wang X, Xu Z, . Budgetary impact from multiple perspectives of sustained antitobacco national media campaigns to reduce the harms of cigarette smoking. Tobacco Control 2020.
Mackay DF, Turner SW, Semple SE, Dick S, Pell JP. Associations between smoke-free vehicle legislation and childhood admissions to hospital for asthma in Scotland: an interrupted time-series analysis of whole-population data. Lancet Public Health 2021;6(8):e579–e586.34274049
Mackert M, Case K, Lazard A, Oh J, Hughes Wagner J, Hawk E, Cofer J, Hurst A, Elerian N, Lakey D. Building a health communication brand for University of Texas System tobacco control. Journal of American College Health 2019;67(4):291–8.29952736
Maclean JC, Pesko MF, Hill SC. The Effect of Insurance Expansions on Smoking Cessation Medication Prescriptions: Evidence from ACA Medicaid Expansions. Working Paper No. 23450. Cambridge (MA): National Bureau of Economic Research, 2017.
MacMonegle AJ, Nonnemaker J, Duke JC, Farrelly MC, Zhao X, Delahanty JC, Smith AA, Rao P, Allen JA. Cost-effectiveness analysis of the real cost campaign’s effect on smoking prevention. American Journal of Preventive Medicine 2018;55(3):319–25.30122214
MacNaughton P, Adamkiewicz G, Arku RE, Vallarino J, Levy DE. The impact of a smoke-free policy on environmental tobacco smoke exposure in public housing developments. Science of the Total Environment 2016;557–558:676–80.
Madison K, Schmidt H, Volpp KG. Smoking, obesity, health insurance, and health incentives in the Affordable Care Act. JAMA: the Journal of the American Medical Association 2013;310(2):143–4.23765171
Madison KM, Volpp KG, Halpern SD. The law, policy, and ethics of employers’ use of financial incentives to improve health. Journal of Law, Medicine & Ethics 2011;39(3):450–68.
Maes S, Verhoeven C, Kittel F, Scholten H. Effects of a Dutch worksite wellness-health program: The Brabantia project. American Journal of Public Health 1998;88(7):1037–41.9663150
Main C, Thomas S, Ogilvie D, Stirk L, Petticrew M, Whitehead M, Sowden A. Population tobacco control interventions and their effects on social inequalities in smoking: placing an equity lens on existing systematic reviews. BMC Public Health 2008;8:178.18505545
Malinowski B, Minkler M, Stock L. Labor unions: a public health institution. American Journal of Public Health 2015;105(2):261–71.25521905
Mamudu HM, Osedeme F, Robertson C, Littleton MA, Owusu D, Wang L, Studlar DT. A qualitative study to explore perception of impacts of preemption of tobacco regulation on counties in Appalachian Tennessee. International Journal of Environmental Research and Public Health 2020;17(9):3230.32384710
Mandel LL, Alamar BC, Glantz SA. Smoke-free law did not affect revenue from gaming in Delaware. Tobacco Control 2005;14(1):10–2.15735294
Mann N, Malarcher A, Zhang L, Shaikh A, Thompson J, Chapman L. National trends and state-level variation in the duration of incoming quitline calls to 1-800-QUIT-NOW during 2012–2015. Journal of Smoking Cessation 2020;15(2):59–66.
Mannes M. Research on and evidence for the developmental assets model. In: Chinman M, Imm P, editors. Getting to Outcomes with Developmental Assets: Ten Steps to Measuring Success in Youth Programs and Communities. Minneapolis (MN): Search Institute, 2006.
Mantey DS, Cooper MR, Clendennen SL, Pasch KE, Perry CL. E-cigarette marketing exposure is associated with e-cigarette use among U.S. youth. Journal of Adolescent Health 2016;58(6):686–90.
Manuele FA, editor. Advanced Safety Management Focusing on Z10 and Serious Injury Prevention. 2nd ed. Hoboken (NJ): John Wiley & Sons, Inc., 2014; 44–51.
Marmot M, Allen J, Bell R, Bloomer E, Goldblatt P, Consortium for the European Review of Social Determinants of H, the Health D. WHO European review of social determinants of health and the health divide. Lancet 2012;380(9846):1011–29.22964159
Marmot M, Bell R. Challenging health inequalities—implications for the workplace. Occupational Medicine (Oxford, England) 2010;60(3):162–4.20423942
Martin E, Jacobson L, Singh G, Sheikhatari P, Girmay M. Smoking-free policies and smoking behaviors among Historically Black Colleges and Universities students in the United States. International Journal of Translational Medical Research and Public Health 2020;4(2):187–99.
Marynak K, Gentzke A, Wang TW, Neff L, King BA. Exposure to electronic cigarette advertising among middle and high school students—United States, 2014–2016. Morbidity and Mortality Weekly Report 2018a;67(10):294–9.29543786
Marynak K, VanFrank B, Tetlow S, Mahoney M, Phillips E, Jamal Mbbs A, Schecter A, Tipperman D, Babb S. Tobacco cessation interventions and smoke-free policies in mental health and substance abuse treatment facilities—United States, 2016. Morbidity and Mortality Weekly Report 2018b;67(18):519–23.29746451
Marynak KL, Xu X, Wang X, Holmes CB, Tynan MA, Pechacek T. Estimating the impact of raising prices and eliminating discounts on cigarette smoking prevalence in the United States. Public Health Reports 2016;131(4):536–43.27453597
Matt GE, Quintana PJE, Hoh E, Zakarian JM, Dodder NG, Record RA, Hovell MF, Mahabee-Gittens EM, Padilla S, Markman L, . Persistent tobacco smoke residue in multiunit housing: legacy of permissive indoor smoking policies and challenges in the implementation of smoking bans. Preventive Medicine Reports 2020;18:101088.32368436
Matthews AK, Steffen A, Kuhns L, Ruiz R, Ross N, Burke L, Li CC, King AC. Evaluation of a randomized clinical trial comparing the effectiveness of a culturally targeted and non-targeted smoking cessation intervention for lesbian, gay, bisexual and transgender (LGBT) smokers. Nicotine & Tobacco Research 2019;21(11):1506–16.30169797
McAfee T, Babb S, McNabb S, Fiore MC. Helping smokers quit—opportunities created by the Affordable Care Act. New England Journal of Medicine 2015;372(1):5–7.25409263
McAfee T, Davis KC, Alexander RL Jr, Pechacek TF, Bunnell R. Effect of the first federally funded U.S. antismoking national media campaign. Lancet 2013;382(9909):2003–11.24029166
McAfee T, Davis KC, Shafer P, Patel D, Alexander R, Bunnell R. Increasing the dose of television advertising in a national antismoking media campaign: results from a randomised field trial. Tobacco Control 2017;26(1):19–28.26678518
McAfee T, Fellows J, Zbikowski SM. Rapid Response: Re: Effect of offering different levels of support and free nicotine replacement therapy via an English national telephone quitline: randomised controlled trial [editorial]. BMJ 2012;344(e1696).
McAfee T, Malone RE, Cataldo J. Ignoring our elders: tobacco control’s forgotten health equity issue. Tobacco Control 2021;30(5):479–80.34389689
McCarrier KP, Zimmerman FJ, Ralston JD, Martin DP. Associations between minimum wage policy and access to health care: evidence from the Behavioral Risk Factor Surveillance System, 1996-2007. American Journal of Public Health 2011;101(2):359–67.21164102
McCarthy DE, Adsit RT, Zehner ME, Mahr TA, Skora AD, Kim N, Baker TB, Fiore MC. Closed-loop electronic referral to SmokefreeTXT for smoking cessation support: a demonstration project in outpatient care. Translational Behavioral Medicine 2019.
McCarthy WJ, Mistry R, Lu Y, Patel M, Zheng H, Dietsch B. Density of tobacco retailers near schools: effects on tobacco use among students. American Journal of Public Health 2009;99(11):2006–13.19820214
McDaniel PA, Malone RE. Understanding community norms surrounding tobacco sales. PLoS One 2014;9(9):e106461.25180772
McDonnell D, Kazinets G, Lee H-J, Moskowitz J. An internet-based smoking cessation program for Korean Americans: results from a randomized controlled trial. Nicotine & Tobacco Research 2011;13(5): 336–43:336–43.21330285
McDonnell KK, Bullock LF, Kozower BD, Hollen PJ, Heath J, Rovnyak V. A decision aid to improve smoking abstinence for families facing cancer. Oncology Nursing Forum 2014;41(6):649–58.25355020
McIntosh S, Wall AF, Johnson T, Kurtzman J, Ververs D, Ossip DJ. Tobacco control at community colleges: context and opportunities. Tobacco Prevention & Cessation 2016;2:79.
McKeganey N, Barnard M, Russell C. Vapers and vaping: e-cigarettes users views of vaping and smoking. Drugs: Education, Prevention and Policy 2018;25(1):13–20.
McKelvey K, Baiocchi M, Halpern-Felsher B. PMI’s heated tobacco products marketing claims of reduced risk and reduced exposure may entice youth to try and continue using these products. Tobacco Control 2020;29(e1):e18–e24.32029537
McLellan D, Harden E, Markkanen P, Sorensen G. SafeWell Practice Guidelines: An Integrated Approach to Worker Health. Version 2.0. Boston (MA): Dana-Farber Cancer Institute, 2012.
McLellan D, Moore W, Nagler E, Sorensen G. Implementing an Integrated Approach: Weaving Worker Health, Safety, and Well-Being Into the Fabric of Your Organization. Boston (MA): Dana-Farber Cancer Institute, 2017.
McLeroy KR, Bibeau D, Steckler A, Glanz K. An ecological perspective on health promotion programs. Health Education Quarterly 1988;15(4):351–77.3068205
Medina-Ramírez P, Sutton SK, Martínez Ú, Meade CD, Byrne MM, Brandon KO, Meltzer LR, Gonzales FM, Brandon TH, Simmons VN. A randomized controlled trial of a smoking cessation self-help intervention for Spanish-speaking Hispanic/Latinx smokers: study design and baseline characteristics. Contemporary Clinical Trials 2019;85:105836.31473331
Mendez D. Results from a Population Dynamics Model of the Consequences of Menthol Cigarettes for Smoking Prevalence and Disease Risks. Appendix A in Tobacco Product Scientific Advisory Committee: Menthol Cigarettes and Public Health: Review of the Scientific Evidence and Recommendations. Washington (DC): U.S. Food and Drug Administration, 2011.
Mendez D, Le TTT. Consequences of a match made in hell: the harm caused by menthol smoking to the African American population over 1980–2018. Tobacco Control 2021.
Mercincavage M, Lochbuehler K, Villanti AC, Wileyto EP, Audrain-McGovern J, Strasser AA. Examining risk perceptions among daily smokers naive to reduced nicotine content cigarettes. Nicotine & Tobacco Research 2019;21(7):985–90.29718357
Mersha TB, Beck AF. The social, economic, political, and genetic value of race and ethnicity in 2020. Human Genomics 2020;14(1):37.33059745
Messer K, Mills AL, White MM, Pierce JP. The effect of smoke-free homes on smoking behavior in the U.S. American Journal of Preventive Medicine 2008;35(3):210–6.18620837
Miller MD, Marty MA, Broadwin R, Johnson KC, Salmon AG, Winder B, Steinmaus C. The association between exposure to environmental tobacco smoke and breast cancer: a review by the California Environmental Protection Agency. Preventive Medicine 2007;44(2):93–106.17027075
Mills AL, Messer K, Gilpin EA, Pierce JP. The effect of smoke-free homes on adult smoking behavior: a review. Nicotine & Tobacco Research 2009;11(10):1131–41.19633273
Mills SD, Golden SD, Queen TL, Kong AY, Ribisl KM. Are state-level income-based disparities in adult smoking declining? Preventive Medicine 2020;133:106019.32057958
Milov S. The Cigarette: A Political History. Cambridge (MA): Harvard University Press, 2019.
Minkler M, Blackwell AG, Thompson M, Tamir H. Community-based participatory research: implications for public health funding. American Journal of Public Health 2003;93(8):1210–3.12893597
Minkler M, Vasquez VB, Chang C, Miller J, Rubin V, Glover Blackwell A, Thompson M, Flournoy R, Bell J. Promoting Healthy Public Policy Through Community-Based Participatory Research: Ten Case Studies. Berkeley (CA): University of California, Berkeley and PolicyLink, 2008.
Mistry R, Pednekar M, Pimple S, Gupta PC, McCarthy WJ, Raute LJ, Patel M, Shastri SS. Banning tobacco sales and advertisements near educational institutions may reduce students’ tobacco use risk: evidence from Mumbai, India. Tobacco Control 2015;24(E1):E100–E107.23958643
Moir D, Rickert WS, Levasseur G, Larose Y, Maertens R, White P, Desjardins S. A comparison of mainstream and sidestream marijuana and tobacco cigarette smoke produced under two machine smoking conditions. Chemical Research in Toxicology 2008;21(2):494–502.18062674
Mok Y, Jeon J, Levy DT, Meza R. Associations between e-cigarette use and e-cigarette flavors with cigarette smoking quit attempts and quit success: evidence from a U.S. large, nationally representative 2018–2019 survey. Nicotine & Tobacco Research 2023;25(3):541–52.36250607
Monson E, Arsenault N. Effects of enactment of legislative (public) smoking bans on voluntary home smoking restrictions: a review. Nicotine & Tobacco Research 2017;19(2):141–8.27613902
Montgomery L, Robinson C, Seaman EL, Haeny AM. A scoping review and meta-analysis of psychosocial and pharmacological treatments for cannabis and tobacco use among African Americans. Psychology of Addictive Behaviors 2017;31(8):922–43.29199844
Moran MB, Heley K, Pierce JP, Niaura R, Strong D, Abrams D. Ethnic and socioeconomic disparities in recalled exposure to and self-reported impact of tobacco marketing and promotions. Health Communication 2019;34(3):280–9.29236530
Moran MB, Sussman S. Translating the link between social identity and health behavior into effective health communication strategies: an experimental application using anti-smoking advertisement. Health Communication 2014;29(10):1057–66.24447056
Moran MB, Sussman S. Changing attitudes toward smoking and smoking susceptibility through peer crowd targeting: more evidence from a controlled study. Health Communication 2015;30(5):521–4.25204200
Morgan SL, Reed GL, Tidey J, Bunn JY, Harfmann RF, Heil SH, Sigmon SC, Gaalema D, Higgins ST. Predictors of adherence among vulnerable populations of adults assigned to smoke very low nicotine content cigarettes. Nicotine & Tobacco Research 2022;24(12):1959–67.35704338
Moritsugu KP. The 2006 Report of the Surgeon General: the health consequences of involuntary exposure to tobacco smoke. American Journal of Preventive Medicine 2007;32(6):542–3.17533072
Morris CD, Lukowski AV, Vargas-Belcher RA, Ylioja TE, Nash CM, Bailey LA. Quitline programs tailored for mental health: initial outcomes and feasibility. American Journal of Preventive Medicine 2021;60 (3 Suppl 2):S163–S171.33663704
Morton M, Montgomery P. Youth empowerment programs for improving self-efficacy and self-esteem of adolescents. Campbell Systematic Reviews 2011;7(1):1–80.
Mosdol A, Lidal IB, Straumann GH, Vist GE. Targeted mass media interventions promoting healthy behaviours to reduce risk of non-communicable diseases in adult, ethnic minorities. Cochrane Database of Systematic Reviews 2017, Issue 2. Art. No.: CD011683. DOI: 10.1002/14651858.CD011683.pub2.
Mowery PD, Babb S, Hobart R, Tworek C, MacNeil A. The impact of state preemption of local smoking restrictions on public health protections and changes in social norms. Journal of Environmental and Public Health 2012;2012:632629.22654921
Mullen PD, Savas LS, Bundy LT, Haardorfer R, Hovell M, Fernandez ME, Monroy JA, Williams RS, Kreuter MW, Jobe D, . Minimal intervention delivered by 2-1-1 information and referral specialists promotes smokefree homes among 2-1-1 callers: a Texas generalisation trial. Tobacco Control 2016;25(Suppl 1):i10–i18.27697943
Murphy-Hoefer R, Davis KC, King BA, Beistle D, Rodes R, Graffunder C. Association between the Tips From Former Smokers campaign and smoking cessation among adults, United States, 2012–2018. Preventing Chronic Disease 2020;17:E97.32857030
Murphy-Hoefer R, Madden P, Maines D, Coles C. Prevalence of smoke-free car and home rules in Maine before and after passage of a smoke-free vehicle law, 2007–2010. Preventing Chronic Disease 2014;11:130132.24433624
Murphy SE, Park SL, Balbo S, Haiman CA, Hatsukami DK, Patel Y, Peterson LA, Stepanov I, Stram DO, Tretyakova N, . Tobacco biomarkers and genetic/epigenetic analysis to investigate ethnic/racial differences in lung cancer risk among smokers. NPJ Precision Oncology 2018;2:17.30155522
Mushtaq N, Boeckman LM, Beebe LA. Predictors of smokeless tobacco cessation among telephone quitline participants. American Journal of Preventive Medicine 2015;48(1 Suppl 1):S54–S56.25528708
Myers AE, Hall MG, Isgett LF, Ribisl KM. A comparison of three policy approaches for tobacco retailer reduction. Preventive Medicine 2015;74:67–73.25689540
Nahhas GJ, Wilson D, Talbot V, Cartmell KB, Warren GW, Toll BA, Carpenter MJ, Cummings KM. Feasibility of implementing a hospital-based “opt-out” tobacco-cessation service. Nicotine & Tobacco Research 2017;19(8):937–43.27928052
Nanninga S, Lehne G, Ratz T, Bolte G. Impact of public smoking bans on social inequalities in children’s exposure to tobacco smoke at home: an equity-focused systematic review. Nicotine & Tobacco Research 2019;21(11):1462–72.29986089
Nanninga S, Lhachimi SK, Bolte G. Impact of public smoking bans on children’s exposure to tobacco smoke at home: a systematic review and meta-analysis. BMC Public Health 2018;18(1):749.29925343
National Academy of Medicine. Achieving health equity and systems transformation through community engagement: a conceptual model, n.d.; <https://nam.edu/programs/value-science-driven-health-care/achieving-health-equity-and-systems-transformation-through-community-engagement-a-conceptual-model/>; accessed: July 7, 2022.
National Association of Tobacco Outlets, Inc. v. City of Providence, R.I., 731 F.3d 71 (1st Cir. 2013).
National Cancer Institute. State and Local Legislative Action to Reduce Tobacco Use. Tobacco Control Monograph No. 11. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2000. NIH Publication No. 00-4804.
National Cancer Institute. The Role of the Media in Promoting and Reducing Tobacco Use. Tobacco Control Monograph No. 19. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2008. NIH Publication No. 07-6242.
National Cancer Institute. Chapter 8: Occupation, the work environment and tobacco-related health disparities. In: A Socioecological Approach to Addressing Tobacco-Related Health Disparities. Tobacco Control Monograph 22. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2017a. NIH Publication No. 17-CA-8035A.
National Cancer Institute. A Socioecological Approach to Addressing Tobacco-Related Health Disparities. Tobacco Control Monograph 22. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2017b. NIH Publication No. 17-CA-8035A.
National Cancer Institute. Treating Smoking in Cancer Patients: An Essential Component of Cancer Care. Tobacco Control Monograph 23. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2022.
National Cancer Institute and World Health Organization. The Economics of Tobacco and Tobacco Control. Tobacco Control Monograph 21. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute; and Geneva (Switzerland): World Health Organization, 2016. NIH Publication No. 16-CA-8029A.
National Center for Education Statistics. A Profile of the Enrollment Patterns and Demographic Characteristics of Undergraduates at For-Profit Institutions, 2017; <https://nces.ed.gov/pubs2017/2017416.pdf>; accessed: March 31, 2023.
National Center for Education Statistics. Characteristics of postsecondary students, 2022; <https://nces.ed.gov/programs/coe/indicator/csb>; accessed: July 12, 2022.
National Center for Education Statistics. Table 1. Number and percentage distribution of Title IV institutions, by control of institution, level of institution, and region: United States and other U.S. jurisdictions, academic year 2020–21, n.d.; <https://nces.ed.gov/ipeds/Search/ViewTable?tableId=28457>; accessed: July 12, 2022.
National Human Genome Research Institute. Race, July 1, 2023; <https://www.genome.gov/genetics-glossary/Race>; accessed: July 3, 2023.
National Institute for Health Care and Excellence. Guidance: 1.4 recommendations on preventing uptake: coordinated approach to school-based interventions. In: Tobacco: Preventing Uptake, Promoting Quitting and Treating Dependence (NICE Guideline NG209), 2022a; <https://www.nice.org.uk/guidance/ng209/chapter/Recommendations-on-preventing-uptake#coordinated-approach-to-school-based-interventions>; accessed: July 12, 2022.
National Institute for Health Care and Excellence. Guidance: 1.6 recommendations on preventing uptake: adult-led interventions in schools. In: Tobacco: Preventing Uptake, Promoting Quitting and Treating Dependence (NICE Guideline NG209), 2022b; <https://www.nice.org.uk/guidance/ng209/chapter/Recommendations-on-preventing-uptake#adult-led-interventions-in-schools>; accessed: July 12, 2022.
National Institute for Occupational Safety and Health. Essential elements of effective workplace programs and policies for improving worker health and wellbeing, 2008; <https://www.cdc.gov/niosh/docs/2010-140/default.html>; accessed: April 17, 2020.
National Institute for Occupational Safety and Health. NIOSH 2012. Research Compendium: The NIOSH Total Worker Health^TM^ Program: Seminal Research Papers (Publication No. 2012-146), 2012; <http://www.cdc.gov/niosh/docs/2012-146/pdfs/2012-146.pdf>; accessed: April 17, 2020.
National Institute for Occupational Safety and Health. Total worker health: let’s get started, 2016; <https://www.cdc.gov/niosh/twh/letsgetstarted.html>; accessed: April 17, 2020.
National Institute for Occupational Safety and Health. Total worker health, 2017; <https://www.cdc.gov/niosh/twh/totalhealth.html>; accessed: April 17, 2020.
National Institute of Environmental Health Sciences. Community-engaged research and citizen science, n.d.; <https://www.niehs.nih.gov/research/supported/translational/community/index.cfm>; accessed: January 9, 2023.
National Institutes of Health. Intramural Research Program: Effects of tobacco discount coupons and policy intervention on tobacco use disparities, 2017; <https://irp.nih.gov/accomplishments/effects-of-tobacco-discount-coupons-and-policy-intervention-on-tobacco-use-disparities>; accessed: July 12, 2022.
National Institutes of Health, U.S. Food and Drug Administration. Ever use of any cigars among adults (aged 25+), by sociodemographics: changes between waves. In Ever Use of Any Cigars Among Adults (Aged 25+), by Sociodemographics, 2021; <https://www.icpsr.umich.edu/files/NAHDAP/pathstudy/OlderAdult-Ever-AnyCigar.pdf>; accessed: June 16, 2023.
National Native Network. Your Commercial Tobacco Smoke-Free Tribal Policy Toolkit (4th edition), n.d.; <https://keepitsacred.itcmi.org/resources/smoke-free-policy-toolkit>; accessed: July 8, 2022.
Navajo Nation Office of Legislative Services. Legislation details: Air is Life Act of 2021, November 6, 2021; <http://dibb.nnols.org/PublicViewBill.aspx?serviceID=3cb40274-8287-40e6-b676-a8843e8df9e1>; accessed: July 8, 2022.
Navajo Nation Office of the President and Vice President and Office of the Speaker. Air is Life Act signed into law to promote a healthier and commercial smokefree Navajo Nation [press release], November 6, 2021; <https://www.navajonationcouncil.org/wp-content/uploads/2021/11/Joint_PR_Draft2.pdf>; accessed: July 8, 2022.
Nelson A, Babon A, Berry M, Keath N. Engagement, but for what kind of marriage? Community members and local planning authorities. Community Development Journal 2008;43(1):37–51.
Network for Public Health Law and National Association of County and City Health Officials. Proposed Limits on Public Health Authority: Dangerous for Public Health. Edina (MN) and Washington (DC): Network for Public Health Law and NACCHO, 2021; <https://www.naccho.org/uploads/downloadable-resources/Proposed-Limits-on-Public-Health-Authority-Dangerous-for-Public-Health-FINAL-5.24.21pm.pdf>; accessed: July 7, 2022.
New Orleans Health Department. Overview of the New Orleans Smoke-Free Ordinance, April 13, 2015; <https://nola.gov/getattachment/Health/Smoke-Free-Ordinance/NOHDSmokeFreeOrdinanceChart-4-13-15.pdf/>; accessed: July 8, 2022.
Newman Carroll S, Mombourquette A, Boxer M, Williams R, Brewer S. Indigenous empowerment through community-engaged health education curriculum: health promotion in a commercial tobacco cessation campaign. Pedagogy in Health Promotion 2021;7(4):358–65.
Nez Henderson P, Roeseler A, Moor G, Clark HW, Yazzie A, Nez P, Nez C, Sabo S, Leischow SJ. Advancing smokefree policy adoption on the Navajo Nation. Tobacco Control 2016;25(Suppl 1):i26–i31.27697945
Nguyen HV, Grootendorst P. Intended and unintended effects of restrictions on the sale of cigarillos to youth: evidence from Canada. Tobacco Control 2015;24(4):382–8.24610053
Niederdeppe J, Farrelly MC, Nonnemaker J, Davis KC, Wagner L. Socioeconomic variation in recall and perceived effectiveness of campaign advertisements to promote smoking cessation. Social Science & Medicine 2011;72(5):773–80.21316830
Niederdeppe J, Kuang X, Crock B, Skelton A. Media campaigns to promote smoking cessation among socioeconomically disadvantaged populations: what do we know, what do we need to learn, and what should we do now? Social Science & Medicine 2008;67(9):1343–55.18691793
Nollen N, Ahluwalia JS, Mayo MS, Richter K, Choi WS, Okuyemi KS, Resnicow K. A randomized trial of targeted educational materials for smoking cessation in African Americans using transdermal nicotine. Health Education & Behavior 2007;34(6):911–27.17576774
Nollen NL, Ahluwalia JS, Sanderson Cox L, Okuyemi K, Lawrence D, Samuels L, Benowitz NL. Assessment of racial differences in pharmacotherapy efficacy for smoking cessation: secondary analysis of the EAGLES Randomized Clinical Trial. JAMA Network Open 2021;4(1):e2032053.33464316
Nollen NL, Cox LS, Mayo MS, Ellerbeck EF, Ahluwalia JS. Counseling alone or in combination with nicotine replacement therapy for treatment of Black non-daily smokers: a randomized trial. Addiction 2020;115(8):1547–60.31899564
Nollen NL, Cox LS, Nazir N, Ellerbeck EF, Owen A, Pankey S, Thompson N, Ahluwalia JS. A pilot clinical trial of varenicline for smoking cessation in Black smokers. Nicotine & Tobacco Research 2011;13(9):868–73.21498427
Nollen NL, Mayo MS, Sanderson Cox L, Benowitz NL, Tyndale RF, Ellerbeck EF, Scheuermann TS, Ahluwalia JS. Factors that explain differences in abstinence between black and white smokers: a prospective intervention study. Journal of the National Cancer Institute 2019;111(10):1078–87.30657926
Nonnemaker J, Kim A, Shafer P, Loomis B, Hill E, Holloway J, Farrelly M. Influence of point-of-sale tobacco displays and plain black and white cigarette packaging and advertisements on adults: evidence from a virtual store experimental study. Addictive Behaviors 2016;56:15–22.26785362
North American Quitline Consortium. Results from the FY2015 NAQC annual survey of quitlines, 2015; <http://www.naquitline.org/?page=2015Survey>; accessed: July 12, 2022.
North American Quitline Consortium. Quitline Services: Current Practice and Evidence Base, 2016. Phoenix (AZ): North American Quitline Consortium, 2016.
North American Quitline Consortium. Results from the 2018 NAQC annual survey of quitlines, 2018; <http://www.naquitline.org/?page=2018Survey>; accessed: May 4, 2020.
North American Quitline Consortium. NAQC FY2020 Annual Survey: Progress Update, 2021; <https://cdn.ymaws.com/www.naquitline.org/resource/resmgr/2020_survey/552021naqcfy2020asslides.pdf>; accessed: July 12, 2022.
North American Quitline Consortium. NAQC FY22 Annual Survey: A National Progress Update, July 31, 2023; <https://cdn.ymaws.com/www.naquitline.org/resource/resmgr/2022_webinars/Final_FY22_Results_Webinarre.pdf>; accessed: August 10, 2023.
North American Quitline Consortium. 2017 survey, n.d.a; <https://www.naquitline.org/page/2017survey>; accessed: July 12, 2022.
North American Quitline Consortium. Minimal data set, n.d.b; <https://www.naquitline.org/page/mds>; accessed: July 31, 2022.
North American Quitline Consortium. Quitline profiles, n.d.c; <https://www.naquitline.org/page/quitlineprofiles>; accessed: June 28, 2023.
Northridge ME, Vallone D, Xiao H, Green M, Weikle Blackwood J, Kemper SE, Duke J, Watson KA, Burrus B, Treadwell HM. The importance of location for tobacco cessation: rural–urban disparities in quit success in underserved West Virginia counties. Journal of Rural Health 2008;24(2):106–15.
Northrup TF, Jacob P, Benowitz NL, Hoh E, Quintana PJE, Hovell MF, Matt GE, Stotts AL. Thirdhand smoke: state of the science and a call for policy expansion. Public Health Reports 2016;131(2):233–8.26957657
Notley C, Gentry S, Livingstone-Banks J, Bauld L, Perera R, Hartmann-Boyce J. Incentives for smoking cessation. Cochrane Database of Systematic Reviews 2019, Issue 7. Art. No.:CD004307. DOI: 10.1002/14651858.CD004307.pub6.
Novak SP, Reardon SF, Raudenbush SW, Buka SL. Retail tobacco outlet density and youth cigarette smoking: a propensity-modeling approach. American Journal of Public Health 2006;96(4):670–6.16507726
O’Donald ER, Miller CP, O’Leary R, Ong J, Pacheco B, Foos K, Enright K, O’Leary M, Nez Henderson P, Lewis J, . Active smoking, secondhand smoke exposure and serum cotinine levels among Cheyenne River Sioux communities in context of a Tribal Public Health Policy. Tobacco Control 2020;29(5):570–6.31462578
Odani S, Soura BD, Tynan MA, Lavinghouze R, King BA, Agaku I. Tobacco and marijuana use among U.S. college and noncollege young adults, 2002–2016. Pediatrics 2019;144(6):e20191372.31712275
Office of Disease Prevention and Health Promotion. Eliminate policies in states, territories, and DC that preempt local tobacco control policies—TU-20, n.d.; <https://health.gov/healthypeople/objectives-and-data/browse-objectives/tobacco-use/eliminate-policies-states-territories-and-dc-preempt-local-tobacco-control-policies-tu-20>; accessed: July 7, 2022.
Okechukwu CA, Krieger N, Sorensen G, Li Y, Barbeau EM. MassBuilt: effectiveness of an apprenticeship site-based smoking cessation intervention for unionized building trades workers. Cancer Causes Control 2009;20(6):887–94.19301135
Olsen DP. The ethics of denying smokers employment in health care. American Journal of Nursing 2014;114(6):55–8.
Olson LT, Coats EM, Rogers T, Brown EM, Nonnemaker J, Ross AM, Delahanty J, Xu X. Youth tobacco use before and after local sales restrictions on flavored and menthol tobacco products in Minnesota. Journal of Adolescent Health 2022a;70(6):978–84.
Olson LT, Gammon DG, Rogers T, Brown EM, Nonnemaker JM, Spinks JG, Ross A, Xu X, Moze J, Matter CM, . Expanding local sales restrictions on flavoured tobacco products to include menthol: retail sales changes in two Minnesota cities. Tobacco Control 2022b.
Olson R, Anger WK, Elliot DL, Wipfli B, Gray M. A new health promotion model for lone workers: results of the Safety & Health Involvement For Truckers (SHIFT) pilot study. Journal of Occupational and Environmental Medicine 2009;51(11):1233–46.19858740
Ong MK, Zhou Q, Sung H-Y. Sensitivity to cigarette prices among individuals with alcohol, drug, or mental disorders. American Journal of Public Health 2010;100(7):1243–5.20466972
Orleans CT, Schoenbach VJ, Wagner EH, Quade D, Salmon MA, Pearson DC, Fiedler J, Porter CQ, Kaplan BH. Self-help quit smoking interventions: effects of self-help materials, social support instructions, and telephone counseling. Journal of Consulting and Clinical Psychology 1991;59(3):439–48.2071729
Orr MF, Burduli E, Hirchak KA, Walsh Dotson JA, Young SL, Nelson L, Lennstrom E, Slaney T, Bush T, Gillaspy SR, . Culturally-tailored text-messaging intervention for smoking cessation in rural American Indian communities: rationale, design, and methods. Contemporary Clinical Trials Communications 2019;15:100363.31049463
Orton S, Jones LL, Cooper S, Lewis S, Coleman T. Predictors of children’s secondhand smoke exposure at home: a systematic review and narrative synthesis of the evidence. PLoS One 2014;9(11):e112690.25397875
Osinubi OY, Moline J, Rovner E, Sinha S, Perez-Lugo M, Demissie K, Kipen HM. A pilot study of telephone-based smoking cessation intervention in asbestos workers. Journal of Occupational and Environmental Medicine 2003;45(5):569–74.12762083
Ossip-Klein DJ, Giovino GA, Megahed N, Black PM, Emont SL, Stiggins J, Shulman E, Moore L. Effects of smokers’ hotline: results of a 10-county self-help trial. Journal of Consulting and Clinical Psychology 1991;59(2):325–32.2030195
Owusu D, Huang J, Weaver SR, Pechacek TF, Ashley DL, Nayak P, Eriksen MP. Patterns and trends of dual use of e-cigarettes and cigarettes among U.S. adults, 2015–2018. Preventive Medicine Reports 2019;16:101009.31763161
Pacheco CM, Wellever A, Nazir N, Pacheco J, Berryhil K, Faseru B, Barnes C, Daley CM, Choi WS. Clearing the air: American Indian tribal college students’ exposure to second hand smoke & attitudes towards smoke free campus policies. Journal of American College Health 2018;66(2):133–40.29111947
Pakko MR. Smoke-free law did affect revenue from gaming in Delaware. Tobacco Control 2006;15(1):68–9; author reply 9.16436409
Pakko MR. No smoking at the slot machines: the effect of a smoke-free law on Delaware gaming revenues. Applied Economics 2008;40(1769–74).
Palmatier MI, Lantz JE, O’Brien LC, Metz SP. Effects of nicotine on olfactogustatory incentives: preference, palatability, and operant choice tests. Nicotine & Tobacco Research 2013;15(9):1545–54.23430737
Pan J, Barbeau EM, Levenstein C, Balbach ED. Smoke-free airlines and the role of organized labor: a case study. American Journal of Public Health 2005;95(3):398–404.15727966
Park-Lee E, Ren C, Cooper M, Cornelius M, Jamal A, Cullen KA. Tobacco product use among middle and high school students—United States, 2022. Morbidity and Mortality Weekly Report 2022;71(45):1429–35.36355596
Parks MJ, Kegler MC, Kingsbury JH, Borowsky IW. Reducing socioeconomic disparities in comprehensive smoke-free rules among households with children: a pilot intervention implemented through a national cancer program. International Journal of Environmental Research and Public Health 2020;17(18):6787.32957658
Parks MJ, Kingsbury JH, Boyle RG, Evered S. Smokefree rules in homes and cars among smokers and nonsmokers in Minnesota. Preventing Chronic Disease 2018;15:E32.29543585
Parks MJ, Patrick ME, Levy DT, Thrasher JF, Elliott MR, Fleischer NL. Tobacco taxation and its prospective impact on disparities in smoking initiation and progression among young adults. Journal of Adolescent Health 2021;68(4):765–72.
Parks MJ, Patrick ME, Levy DT, Thrasher JF, Elliott MR, Fleischer NL. Cigarette pack price and its within-person association with smoking initiation, smoking progression, and disparities among young adults. Nicotine & Tobacco Research 2022;24(4):519–28.34633457
Patel M, Donovan EM, Liu M, Solomon-Maynard M, Schillo BS. Policy support for smoke-free and e-cigarette free multiunit housing. American Journal of Health Promotion 2022;36(1):106–16.34344161
Patel RR, Schmidt H. Should employers be permitted not to hire smokers? A review of U.S. legal provisions. International Journal of Health Policy Management 2017;6(12):701–6.29172377
Patient Protection and Affordable Care Act, Public Law 111–148, U.S. Statutes at Large 110 (2010).
Patten CA, Boyle R, Tinkelman D, Brockman TA, Lukowski A, Decker PA, D’Silva J, Lichtenstein E, Zhu S-H. Linking smokers to a quitline: randomized controlled effectiveness trial of a support person intervention that targets non-smokers. Health Education Research 2017;32(4):318–31.28854569
Patten CA, Lando HA, Desnoyers CA, Barrows Y, Klejka J, Decker PA, Hughes CA, Bock MJ, Boyer R, Resnicow K, . The Healthy Pregnancies Project: study protocol and baseline characteristics for a cluster-randomized controlled trial of a community intervention to reduce tobacco use among Alaska Native pregnant women. Contemporary Clinical Trials 2019;78:116–25.30703523
Pearlman DN, Arnold JA, Guardino GA, Welsh EB. Advancing tobacco control through point of sale policies, Providence, Rhode Island. Preventing Chronic Disease 2019;16:E129.31538567
Pearson AL, Cleghorn CL, van der Deen FS, Cobiac LJ, Kvizhinadze G, Nghiem N, Blakely T, Wilson N. Tobacco retail outlet restrictions: health and cost impacts from multistate life-table modelling in a national population. Tobacco Control 2017;26:579–85.
Pearson JL, Abrams DB, Niaura RS, Richardson A, Vallone DM. A ban on menthol cigarettes: impact on public opinion and smokers’ intention to quit. American Journal of Public Health 2012;102(11):e107–e114.22994173
Pearson JL, Abrams DB, Niaura RS, Richardson A, Vallone DM. Public support for mandated nicotine reduction in cigarettes. American Journal of Public Health 2013;103(3):562–7.23327262
Peelen MJ, Sheikh A, Kok M, Hajenius P, Zimmermann LJ, Kramer BW, Hukkelhoven CW, Reiss IK, Mol BW, Been JV. Tobacco control policies and perinatal health: a national quasi-experimental study. Scientific Reports 2016;6:23907.27103591
Pennsylvania General Assembly. Fiscal Code—Omnibus Amendments Act, Public Law 281, No. 42, June 22, 2018; <https://www.legis.state.pa.us/cfdocs/legis/li/uconsCheck.cfm?yr=2018&sessInd=0&act=42>; accessed: April 22, 2020.
Perrin A. Digital gap between rural and nonrural America persists, May 31, 2019; <https://www.pewresearch.org/fact-tank/2019/05/31/digital-gap-between-rural-and-nonrural-america-persists/>; accessed: July 19, 2021.
Pertschuk M, Pomeranz J, Aoki JR, Larkin MA, Paloma M. Assessing the impact of federal and state preemption in public health: a framework for decision makers. Journal of Public Health Management and Practice 2013;19(3):213–9.22759986
Pesko MF, Bains J, Maclean C, Cook BL. Nearly half of small employers using tobacco surcharges do not provide tobacco cessation wellness programs. Health Affairs 2018;37(3):473–81.29505370
Pesko MF, Courtemanche CJ, Catherine Maclean J. The effects of traditional cigarette and e-cigarette tax rates on adult tobacco product use. Journal of Risk and Uncertainty 2020;60(3):229–58.33584006
Pesko MF, Licht AS, Kruger JM. Cigarette price minimization strategies in the United States: price reductions and responsiveness to excise taxes. Nicotine & Tobacco Research 2013;15(11):1858–66.23729501
Pew Research Center. Mobile fact sheet: mobile phone ownership over time, April 7, 2021; <https://www.pewresearch.org/internet/fact-sheet/mobile/>; accessed: July 19, 2021.
Pfeffer J. Dying for a Paycheck: How Modern Management Harms Employee Health and Company Performance—and What We Can Do About It. New York (NY): HarperCollins Publishers, 2018.
Pimentel L, Apollonio DE. Placement and sales of tobacco products and nicotine replacement therapy in tobacco-free and tobacco-selling pharmacies in Northern California: an observational study. BMJ Open 2019;9(6):e025603.
Pineiro B, Vidrine DJ, Wetter DW, Hoover DS, Frank-Pearce SG, Nguyen N, Zbikowski SM, Vidrine JI. Implementation of Ask-Advise-Connect in a safety net healthcare system: quitline treatment engagement and smoking cessation outcomes. Translational Behavioral Medicine 2020;10(1):163–7.30476236
Pizacani B, Laughter D, Menagh K, Stark M, Drach L, Hermann-Franzen C. Moving multiunit housing providers toward adoption of smoke-free policies. Preventing Chronic Disease 2011;8(1):A21.21159233
Pizacani BA, Maher JE, Rohde K, Drach L, Stark MJ. Implementation of a smoke-free policy in subsidized multiunit housing: effects on smoking cessation and secondhand smoke exposure. Nicotine & Tobacco Research 2012;14(9):1027–34.22318686
Polinski JM, Howell B, Gagnon MA, Kymes SM, Brennan TA, Shrank WH. Impact of CVS Pharmacy’s discontinuance of tobacco sales on cigarette purchasing (2012–2014). American Journal of Public Health 2017;107(4):556–62.28207340
Pollak KI, Lyna P, Bilheimer AK, Gordon KC, Peterson BL, Gao X, Swamy GK, Denman S, Gonzalez A, Rocha P, . Efficacy of a couple-based randomized controlled trial to help Latino fathers quit smoking during pregnancy and postpartum: the Parejas trial. Cancer Epidemiology, Biomarkers & Prevention 2015;24(2):379–85.
Pomeranz JL. The consequences of preemption on population health, March 3, 2020; <https://jphmpdirect.com/2020/03/03/the-consequences-of-preemption-on-population-health/>; accessed: August 24, 2023.
Pomeranz JL, Silver D. State legislative strategies to pass, enhance, and obscure preemption of local public health policy-making. American Journal of Preventive Medicine 2020;59(3):333–42.32534862
Pomeranz JL, Zellers L, Bare M, Sullivan PA, Pertschuk M. State preemption: threat to democracy, essential regulation, and public health. American Journal of Public Health 2019;109(2):251–2.30649941
Popova L, Owusu D, Nyman AL, Weaver SR, Yang B, Huang J, Ashley DL. Effects of framing nicotine reduction in cigarettes on anticipated tobacco product use intentions and risk perceptions among U.S. adult smokers. Nicotine & Tobacco Research 2019;21(Suppl 1):S108–S116.31867652
Potter LN, Lam CY, Cinciripini PM, Wetter DW. Intersectionality and smoking cessation: exploring various approaches for understanding health inequities. Nicotine & Tobacco Research 2021;23(1):115–23.32208484
PR Newswire. CVS Caremark to stop selling tobacco at all CVS/pharmacy locations, February 5, 2014; <https://www.prnewswire.com/news-releases/cvs-caremark-to-stop-selling-tobacco-at-all-cvspharmacy-locations-243662651.html>; accessed: November 8, 2023.
PR Newswire. Hawaii health measure includes last-minute provision benefiting big tobacco; legislature should revisit measure and repair the damage: joint statement by Matthew L. Myers, President, Campaign for Tobacco-Free Kids; Harold P. Wimmer, National President and CEO, American Lung Association; Nancy Brown, CEO, American Heart Association, July 13, 2018; <https://www.prnewswire.com/news-releases/hawaii-health-measure-includes-last-minute-provision-benefiting-big-tobacco-legislature-should-revisit-measure-and-repair-the-damage-300680837.html>; accessed: February 26, 2024.
Pritsos CA, Pritsos KL, Spears KE. Smoking rates among gamblers at Nevada casinos mirror U.S. smoking rate. Tobacco Control 2008;17(2):82–5.18276735
Prochaska JJ, Das S, Young-Wolff KC. Smoking, mental illness, and public health. Annual Review of Public Health 2017;38:165–85.
Prochaska JJ, Gates EF, Davis KC, Gutierrez K, Prutzman Y, Rodes R. The 2016 Tips From Former Smokers® campaign: associations with quit intentions and quit attempts among smokers with and without mental health conditions. Nicotine & Tobacco Research 2019;21(5):576–83.30496491
Prokhorov AV, Hudmon KS, Marani SK, Bondy ML, Gatus LA, Spitz MR, Wilkinson AV, Hammond SK, Koehly LM. Eliminating second-hand smoke from Mexican-American households: outcomes from Project Clean Air-Safe Air (CASA). Addictive Behaviors 2013;38(1):1485–92.23085392
Pronk NP. Integrated worker health protection and promotion programs: overview and perspectives on health and economic outcomes. Journal of Occupational and Environmental Medicine 2013;55(12 Suppl):S30–S37.24284747
Public Health Law Center. U.S. Prohibitions on Smoking in Cars with Children, October 2017; <http://www.publichealthlawcenter.org/sites/default/files/resources/Prohibitions-Chart-Smoking-With-Children-Cars-2017.pdf>; accessed: June 16, 2023.
Public Health Law Center. Prohibiting Pharmacy Sales of Tobacco Products: Tips and Tools December 2018a; <https://www.publichealthlawcenter.org/sites/default/files/resources/Prohibiting-Pharmacy-Sales-of-Tobacco-Products-2018.pdf>; accessed: November 3, 2020.
Public Health Law Center. U.S. heated cigarette regulations—50-state review, 2018b; <https://www.publichealthlacenter.org/resources/us-heated-cigarette-regulations-50-state-review (https://www.publichealthlawcenter.org/resources/us-heated-cigarette-regulations-50-state-review)>; accessed: July 9, 2022.
Public Health Law Center. Untangling the Preemption Doctrine in Tobacco Control, 2018c; <https://www.publichealthlawcenter.org/sites/default/files/resources/Untangling-the-Preemption-Doctrine-in-Tobacco-Control-2018.pdf>; accessed: July 6, 2022.
Public Health Law Center. Online E-Cigarette Sales & Shipments to Consumers, 2019a; <https://www.publichealthlawcenter.org/sites/default/files/resources/Online-E-Cigarette-Sales-and-Shipments-to-Consumers-State-Laws-Prohibiting-Them.pdf>; accessed: July 12, 2022.
Public Health Law Center. Student Commercial Tobacco Use in Schools: Alternative Measures, 2019b; <https://www.publichealthlawcenter.org/sites/default/files/resources/Addressing-Student-Commercial-Tobacco-Use-in-Schools-Alternative-Measures-2019-0.pdf>; accessed: October 5, 2022.
Public Health Law Center. Smoke-Free Tribal Housing Policies, 2020; <https://www.publichealthlawcenter.org/sites/default/files/resources/Smoke-free-tribal-housing-policies.pdf>; accessed: July 9, 2022.
Public Health Law Center. FDA’s Action on Menthol and Flavored Cigars: What Happens Now?, 2021a; <https://www.publichealthlawcenter.org/sites/default/files/resources/FDA-Action-on-Menthol-And-Flavored-Cigars.pdf>; accessed: July 12, 2022.
Public Health Law Center. Regulating Smoking in Multi-Unit Housing, May 2021b; <https://www.publichealthlawcenter.org/sites/default/files/resources/Regulating-Smoking-in-MUH.pdf>; accessed: July 8, 2022.
Public Health Law Center. 11/9/22—Proposition 31 in California passed! Now what?, November 2022a; <https://www.publichealthlawcenter.org/commentary/221109/11/9/22-proposition-31-california-passed-now-what>; accessed: July 5, 2023.
Public Health Law Center. U.S. e-cigarette regulations—50-state review, 2022b; <https://www.publichealthlawcenter.org/resources/us-e-cigarette-regulations-50-state-review>; accessed: July 9, 2022.
Public Health Law Center. Minnesota Smoke-Free Multiunit Housing: Model Ordinance, April 2023a; <https://www.publichealthlawcenter.org/sites/default/files/resources/MN-SF-MUH-Model-Ordinance.pdf>; accessed: June 16, 2023.
Public Health Law Center. U.S. State Laws Requiring Tobacco-Free Grounds for Mental Health and Substance Use Facilities, 2023b; <https://www.publichealthlawcenter.org/sites/default/files/resources/Tobacco-Free-State-Policies-Mental-Health-Substance-Use-Facilities.pdf>; accessed: August 10, 2023.
Puljevic C, Feulner L, Hobbs M, Erku D, Bonevski B, Segan C, Baker A, Hefler M, Cho A, Gartner C. Tobacco endgame and priority populations: a scoping review. Tobacco Control 2023:tc–2022–057715.
Puljevic C, Morphett K, Hefler M, Edwards R, Walker N, Thomas DP, Khan MA, Perusco A, Le Grande M, Cullerton K, . Closing the gaps in tobacco endgame evidence: a scoping review. Tobacco Control 2022;31(2):365–75.35241614
Pulvers K, Rice M, Stewart SL, Tong E. Tobacco tracker: a new tool to support college smoke and tobacco free policies. Nicotine & Tobacco Research 2022;24(2):241–9.34671812
Quelch JA, Boudreau EC. Building a Culture of Health: A New Imperative for Business. Switzerland: Springer Nature, 2014.
Quinn VP, Hollis JF, Smith KS, Rigotti NA, Solberg LI, Hu W, Stevens VJ. Effectiveness of the 5-As tobacco cessation treatments in nine HMOs. Journal of General Internal Medicine 2009;24(2):149–54.19083066
Rabius V, Wiatrek D, McAlister AL. African American participation and success in telephone counseling for smoking cessation. Nicotine & Tobacco Research 2012;14(2):240–2.21778152
Ramanadhan S, Nagler RH, McCloud R, Kohler R, Viswanath K. Graphic health warnings as activators of social networks: a field experiment among individuals of low socioeconomic position. Social Science & Medicine 2017;175:219–27.28108053
Ramirez AG, Velez LF, Chalela P, Grussendorf J, McAlister AL. Tobacco control policy advocacy attitudes and self-efficacy among ethnically diverse high school students. Health Education & Behavior 2006;33(4):502–14.16740511
Raskind IG, Vishwakarma M, Schleicher NC, Andersen-Rodgers E, Henriksen L. The changing retail landscape for tobacco: dollar stores and the availability of cheap cigarettes among tobacco-related priority populations. Tobacco Control 2022;31(e2):e140–e147.34607887
Rath JM, Pitzer L, Carnegie B, Shinaba M, Vallone D, Parks I, Tertzakian K, Smith D, Stewart-Reid C, Hair EC. Building capacity to implement tobacco-free policies in college and university settings with underserved populations. Tobacco Prevention & Cessation 2019;5:14.32411878
Reddy KP, Schwamm E, Kalkhoran S, Noubary F, Walensky RP, Rigotti NA. Respiratory symptom incidence among people using electronic cigarettes, combustible tobacco, or both. American Journal of Respiratory and Critical Care Medicine 2021; 204(2):231–4.33857396
Reed GL, Colby SM, Sokolovsky AW, Snell LM, DeAtley T, Tidey JW. Predicting non-adherence with very low nicotine content cigarettes among adults with serious mental illness who smoke. Nicotine & Tobacco Research 2022;24(6):914–8.34958368
Rees VW, Connolly GN. Measuring air quality to protect children from secondhand smoke in cars. American Journal of Preventive Medicine 2006;31(5):363–8.17046406
Reisinger SA, Kamel S, Seiber E, Klein EG, Paskett ED, Wewers ME. Cost-effectiveness of community-based tobacco dependence treatment interventions: initial findings of a systematic review. Preventing Chronic Disease 2019;16:E161.31831106
Rendón AD, Unger JB, Cruz T, Soto DW, Baezconde-Garbanati L. Perceptions of secondhand and thirdhand smoke among Hispanic residents of multiunit housing. Journal of Immigrant and Minority Health 2017;19(1):162–9.26545600
Repace J. Respirable particles and carcinogens in the air of Delaware hospitality venues before and after a smoking ban. Journal of Occupational and Environmental Medicine 2004;46(9):887–905.15354053
Repace JL. Secondhand smoke in Pennsylvania casinos: a study of nonsmokers’ exposure, dose, and risk. American Journal of Public Health 2009;99(8):1478–85.19542036
Repace JL, Jiang RT, Acevedo-Bolton V, Cheng KC, Klepeis NE, Ott WR, Hildemann LM. Fine particle air pollution and secondhand smoke exposures and risks inside 66 U.S. casinos. Environmental Research 2011;111(4):473–84.21440253
Resnicow K, Baranowski T, Ahluwalia JS, Braithwaite RL. Cultural sensitivity in public health: defined and demystified. Ethnicity & Disease 1999;9(1):10–21.10355471
Resnicow K, Braithwaite RL, Dilorio C, Glanz K. Applying theory to culturally diverse and unique populations. In: Glanz K, Rimer B, Lewis FM, editors. Health Behavior and Health Education: Theory, Research, and Practice. 3rd ed. San Francisco, CA: Jossey-Bass, 2002:485–509.
Ribisl KM, Golden SD, Huang J, Scollo M. Addressing lower-priced cigarette products through three-pronged comprehensive regulation on excise taxes, minimum price policies and restrictions on price promotions. Tobacco Control 2022;31(2):229–34.35241593
Ribisl KM, Hatsukami DK, Huang J, Williams RS, Donny EC. Strategies to reduce illicit trade of regular nicotine tobacco products after introduction of a low-nicotine tobacco product standard. American Journal of Public Health 2019;109(7):1007–14.31166743
Ribisl KM, Luke DA, Bohannon DL, Sorg AA, Moreland-Russell S. Reducing disparities in tobacco retailer density by banning tobacco product sales near schools. Nicotine & Tobacco Research 2017;19(2):239–44.27613900
Richards MR, Marti J, Maclean JC, Fletcher J, Kenkel D. Tobacco control, Medicaid coverage, and the demand for smoking cessation drugs. American Journal of Health Economics 2017;3(4):528–49.
Richardson A, Cullen J, Mowery P, McCausland K, Vallone DM. The path to quit: how awareness of a large-scale mass-media smoking cessation campaign promotes quit attempts. Nicotine & Tobacco Research 2011;13(11):1098–105.21852272
Richter KP, Catley D, Gajewski BJ, Faseru B, Shireman TI, Zhang C, Scheuermann TS, Mussulman LM, Nazir N, Hutcheson T, . The effects of opt-out vs opt-in tobacco treatment on engagement, cessation, and costs: a randomized clinical trial. JAMA Internal Medicine 2023.
Richter KP, Ellerbeck EF. It’s time to change the default for tobacco treatment. Addiction 2015;110(3):381–6.25323093
Rigotti NA, Clair C, Munafo MR, Stead LF. Interventions for smoking cessation in hospitalised patients. Cochrane Database of Systematic Reviews 2012, Issue 5. Art. No.: CD001837. DOI: 10.1002/14651858.CD001837.pub3.
Rigotti NA, Kelley JHK, Regan S, Inman E, Kalkhoran S, Flaster A, Chaguturu SK. Enhancing employer coverage of smoking cessation treatment: a randomized trial of the Partners in Helping You Quit (PiHQ) program. Preventive Medicine 2020;140:106216.32693177
Rigotti NA, Stoney CM. CHARTing the future course of tobacco-cessation interventions for hospitalized smokers. American Journal of Preventive Medicine 2016;51(4):549–50.27647055
Riker CA, Butler KM, Ricks JM, Record RA, Begley K, Anderson DG, Hahn EJ. Creating effective media messaging for rural smoke-free policy. Public Health Nursing 2015;32(6):613–24.25731895
Ringen K, Anderson N, McAfee T, Zbikowski SM, Fales D. Smoking cessation in a blue-collar population: Results from an evidence-based pilot program. American Journal of Industrial Medicine 2002;42:367–77.12382249
Rivard C, Brown A, Kasza K, Bansal-Travers M, Hyland A. Home tobacco use policies and exposure to secondhand tobacco smoke: findings from waves 1 through 4 of the Population Assessment of Tobacco and Health (PATH) Study. International Journal of Environmental Research and Public Health 2021;18(18).
Robert Wood Johnson Foundation. Building a culture of health, 2016; <https://www.rwjf.org/en/how-we-work/building-a-culture-of-health.html>; accessed: August 20, 2018.
Robertson L, McGee R, Marsh L, Hoek J. A systematic review on the impact of point-of-sale tobacco promotion on smoking. Nicotine & Tobacco Research 2015;17(1):2–17.25173775
Robinson CD, Wiseman KP, Webb Hooper M, El-Toukhy S, Grenen E, Vercammen L, Prutzman YM. Engagement and short-term abstinence outcomes among blacks and whites in the National Cancer Institute’s SmokefreeTXT Program. Nicotine & Tobacco Research 2020;22(9):1622–6.31535690
Robles GI, Singh-Franco D, Ghin HL. A review of the efficacy of smoking-cessation pharmacotherapies in nonwhite populations. Clinical Therapeutics 2008;30(5):800–12.18555928
Roditis M, Delucchi K, Cash D, Halpern-Felsher B. Adolescents’ perceptions of health risks, social risks, and benefits differ across tobacco products. Journal of Adolescent Health 2016a;58(5):558–66.
Roditis M, Lee J, Halpern-Felsher BL. Adolescent (mis) perceptions about nicotine addiction: Results from a mixed-methods study. Health Education & Behavior 2016b;43(2):156–64.26293459
Roditis ML, Halpern-Felsher B. Adolescents’ perceptions of risks and benefits of conventional cigarettes, e-cigarettes, and marijuana: a qualitative analysis. Journal of Adolescent Health 2015;57(2):179–85.
Rodriguez D, Carlos HA, Adachi-Mejia AM, Berke EM, Sargent JD. Predictors of tobacco outlet density nationwide: a geographic analysis. Tobacco Control 2013;22(5):349–55.22491038
Rodriguez Esquivel D, Webb Hooper M, Baker EA, McNutt MD. Culturally specific versus standard smoking cessation messages targeting Hispanics: an experiment. Psychology of Addictive Behaviors 2015;29(2):283–9.26076096
Roeseler A, Burns D. The quarter that changed the world. Tobacco Control 2010;19(Suppl 1):i3–i15.20382647
Rogers ES, Rosen MI, Elbel B, Wang B, Kyanko K, Vargas E, Wysota CN, Sherman SE. Integrating financial coaching and referrals into a smoking cessation program for low-income smokers: a randomized waitlist control trial. Journal of General Internal Medicine 2022a;37(12):2973–81.35018561
Rogers ES, Vargas EA. Tobacco retail environment near housing programmes for patients with mental health conditions in New York City. Tobacco Control 2018;27(5):526–33.28855299
Rogers T, Brown EM, McCrae TM, Gammon DG, Eggers ME, Watson K, Engstrom MC, Tworek C, Holder-Hayes E, Nonnemaker J. Compliance with a sales policy on flavored non-cigarette tobacco products. Tobacco Regulatory Science 2017;3(2 Suppl 1): S84–S93.30320155
Rogers T, Brown EM, Siegel-Reamer L, Rahman B, Feld AL, Patel M, Vallone D, Schillo BA. A comprehensive qualitative review of studies evaluating the impact of local U.S. laws restricting the sale of flavored and menthol tobacco products. Nicotine & Tobacco Research 2022b;24(4):433–43.34525207
Rogers T, Feld A, Gammon DG, Coats EM, Brown EM, Olson LT, Nonnemaker JM, Engstrom M, McCrae T, Holder-Hayes E, . Changes in cigar sales following implementation of a local policy restricting sales of flavoured non-cigarette tobacco products. Tobacco Control 2020;29(4):412–9.31341001
Rokicki S, Adamkiewicz G, Fang SC, Rigotti NA, Winickoff JP, Levy DE. Assessment of residents’ attitudes and satisfaction before and after implementation of a smoke-free policy in Boston multiunit housing. Nicotine & Tobacco Research 2016;18(5):1282–9.26508397
Rose SW, Amato MS, Anesetti-Rothermel A, Carnegie B, Safi Z, Benson AF, Czaplicki L, Simpson R, Zhou Y, Akbar M, . Characteristics and reach equity of policies restricting flavored tobacco product sales in the United States. Health Promotion Practice 2020a; 21(1 Suppl):44S–53S.31908207
Rose SW, Anesetti-Rothermel A, Westneat S, van de Venne J, Folger S, Rahman B, Azam T, Zhou Y, Debnam C, Ribisl K, . Inequitable distribution of FTP marketing by neighborhood characteristics: further evidence for targeted marketing. Nicotine & Tobacco Research 2022a;24(4):484–92.34687204
Rose SW, Ganz O, Zhou Y, Carnegie BE, Villanti AC, Rath J, Hair EC. Longitudinal response to restrictions on menthol cigarettes among young adult U.S. menthol smokers, 2011–2016. American Journal of Public Health 2019;109(10):1400–3.31415195
Rose SW, Ickes M, Patel M, Rayens MK, van de Venne J, Annabathula A, Schillo B. Centering equity in flavored tobacco ban policies: implications for tobacco control researchers. Preventive Medicine 2022b;165(Pt B): 107173.35870576
Rose SW, Johnson AL, Glasser AM, Villanti AC, Ambrose BK, Conway K, Cummings KM, Stanton CA, Delnevo C, Wackowski OA, . Flavour types used by youth and adult tobacco users in Wave 2 of the Population Assessment of Tobacco and Health (PATH) Study 2014–2015. Tobacco Control 2020b;29(4): 432–46.31542778
Rosen LJ, Myers V, Winickoff JP, Kott J. Effectiveness of interventions to reduce tobacco smoke pollution in homes: a systematic review and meta-analysis. International Journal of Environmental Research and Public Health 2015;12(12):16043–59.26694440
Ross H, Tesche J, Vellios N. Undermining government tax policies: common legal strategies employed by the tobacco industry in response to tobacco tax increases. Preventive Medicine 2017;105S(Suppl):S19–S22.28625418
Rossheim ME, Livingston MD, Krall JR, Barnett TE, Thombs DL, McDonald KK, Gimm GW. Cigarette use before and after the 2009 flavored cigarette ban. Journal of Adolescent Health 2020;67(3):432–7.
Roth JL, Brooks-Gunn J. What exactly is a youth development program? Answers from research and practice. Applied Developmental Science 2003;7(2):94–111.
Ruebush E, Mitra S, Meyer C, Sisler L, Goldstein AO. Using a family systems approach to treat tobacco use among cancer patients. International Journal of Environmental Research and Public Health 2020;17(6):2050.32204529
Russette HC, Harris KJ, Schuldberg D, Green L. Policy compliance of smokers on a tobacco-free university campus. Journal of American College Health 2014;62(2):110–6.24456513
Russo ET, Reid M, Taher R, Sharifi M, Shah SN. Referral strategies to a tobacco quitline and racial and/or ethnic differences in participation. Pediatrics 2018; 141(Suppl 1):S30–S39.29292304
Saitz R. Screening and brief intervention enter their 5th decade. Substance Abuse 2007;28:3–6.
San Francisco Tobacco-Free Project. Reducing tobacco retailer density in San Francisco, 2016; <https://sanfranciscotobaccofreeproject.org/case-studies/reducing-tobacco-retail-density-in-san-francisco/>; accessed: July 20, 2021.
San Francisco Tobacco Free Project. San Francisco tobacco control laws, n.d.; <https://sanfranciscotobaccofreeproject.org/sf-tobacco-control-laws/>; accessed: November 3, 2020.
Sanders A, Robinson C, Taylor SC, Post SD, Goldfarb J, Shi R, Hunt YM, Augustson EM. Using a media campaign to increase engagement with a mobile-based youth smoking cessation program. American Journal of Health Promotion 2018;32(5):1273–9.28925292
Sanderson Cox L, Nollen NL, Mayo MS, Choi WS, Faseru B, Benowitz NL, Tyndale RF, Okuyemi KS, Ahluwalia JS. Bupropion for smoking cessation in African American light smokers: a randomized controlled trial. Journal of the National Cancer Institute 2012;104(4):290–8.22282543
Sanderson Cox L, Nollen NL, Mayo MS, Faseru B, Greiner A, Ellerbeck EF, Krebill R, Tyndale RF, Benowitz NL, Ahluwalia JS. Effect of varenicline added to counseling on smoking cessation among African American daily smokers: The Kick It at Swope IV Randomized Clinical Trial. JAMA: the Journal of the American Medical Association 2022;327(22):2201–9.35699705
Satchell T, Diaz MC, Stephens D, Bertrand A, Schillo BA, Whitsel LP. The impact of two state-level approaches to restricting the sale of flavored tobacco products. BMC Public Health 2022;22(1):1799.36138373
Satterfield JM, Gregorich SE, Kalkhoran S, Lum PJ, Bloome J, Alvarado N, Munoz RF, Vijayaraghavan M. Computer-facilitated 5A’s for smoking cessation: a randomized trial of technology to promote provider adherence. American Journal of Preventive Medicine 2018;55(1):35–43.29929682
Saul JE, Guy MC, Bailey L. Trends in quitline funding, FY2009–FY2012: implications for cessation services. Poster presented at the National Conference on Tobacco or Health; August 15–17, 2012; Kansas City (MO).
Saw A, Paterniti DA, Fung L-C, Tsoh JY, Tong EK. Perspectives of Chinese American smoker and nonsmoker household pairs about the creating smokefree living together program. Cancer 2018a; 124(Suppl 7):1599–1606.29578597
Saw A, Stewart SL, Cummins SE, Kohatsu ND, Tong EK. Outreach to California Medicaid smokers for Asian language quitline services. American Journal of Preventive Medicine. 2018b;55(6 Suppl 2):S196–S204.30454674
Scharf D, Fabian T, Fichter-DeSando C, Douaihy A. Nicotine replacement prescribing trends in a large psychiatric hospital, before and after implementation of a hospital-wide smoking ban. Nicotine & Tobacco Research 2011;13(6):466–73.21464201
Schmidt H, Voigt K, Emanuel EJ. The ethics of not hiring smokers. New England Journal of Medicine 2013;368(15):1369–71.23534544
Schnall P, Dobson M, Rosskam E. Unhealthy Work: Causes, Consequences, Cures. In: Elling RH, editor. Critical Approaches in the Health Social Sciences Series. Amityville (NY): Baywood Publishing, 2009:411.
Schoenborn CA, Adams PF, Peregoy JA. Health behaviors of adults: United States, 2008–2010. Vital and Health Statistics. Series 10: Data from the National Health Survey 2013;(257):1–184.
Schroth KR. Ten years of the Tobacco Control Act in New York City. Journal of Legal Medicine 2020;40(3–4):321–33.33797322
Schulenberg JE, Patrick ME, Johnston LD, O’Malley PM, Bachman JG, Miech RA. Monitoring the Future national survey results on drug use, 1975–2020: Volume II, College students and adults ages 19–60. Ann Arbor (MI): Institute for Social Research, The University of Michigan, 2021.
Seaman EL, Corcy N, Chang JT, Chomenko D, Hartman AM, Kittner DL, Reyes-Guzman CM. Menthol cigarette smoking trends among United States adults, 2003–2019. Cancer Epidemiology, Biomarkers & Prevention 2022;31(10):1959–65.
Seidenberg AB, Behm I, Rees VW, Connolly GN. Cigarette sales in pharmacies in the U.S.A. (2005–2009). Tobacco Control 2012;21(5):509–10.21953133
Seidenberg AB, Henriksen L, Ribisl KM. Cigarette promotions in U.S. pharmacies. Nicotine & Tobacco Research 2022;24(4):612–6.34624896
Senft N, Sanderson M, Selove R, Blot WJ, King S, Gilliam K, Kundu S, Steinwandel M, Sternlieb SJ, Warren Andersen S, . Attitudes toward precision treatment of smoking in the Southern community cohort study. Cancer Epidemiology, Biomarkers & Prevention 2019;28(8):1345–52.
Shadel WG, Martino SC, Setodji CM, Scharf DM, Kusuke D, Sicker A, Gong M. Hiding the tobacco power wall reduces cigarette smoking risk in adolescents: using an experimental convenience store to assess tobacco regulatory options at retail point-of-sale. Tobacco Control 2016;25:679–84.
Shafer PR, Davis KC, Patel D, Rodes R, Beistle D. Association between media dose, ad tagging, and changes in web traffic for a National Tobacco Education Campaign: a market-level longitudinal study. Journal of Medical Internet Research 2016;18(2):e39.26887959
Shang C, Ma S, Lindblom EN. Tax incidence of electronic nicotine delivery systems (ENDS) in the U.S.A. Tobacco Control 2021.
Shastri SS, Talluri R, Shete S. Disparities in secondhand smoke exposure in the United States: National Health and Nutrition Examination Survey 2011–2018. JAMA Internal Medicine 2021;181(1):134–7.33226402
Sheffer CE, Anders M, Brackman SL, Steinberg MB, Barone C. Tobacco intervention practices of primary care physicians treating lower socioeconomic status patients. American Journal of the Medical Sciences 2012a;343(5):388–96.22008779
Sheffer CE, Webb Hooper M, Ostroff JS. Commentary: educational and clinical training for addressing tobacco-related cancer health disparities. Ethnicity & Disease 2018;28(3):187–92.30038480
Sheffer MA, Baker TB, Fraser DL, Adsit RT, McAfee TA, Fiore MC. Fax referrals, academic detailing, and tobacco quitline use: a randomized trial. American Journal of Preventive Medicine 2012b;42(1):21–8.22176842
Shiffman S, Kurland BF, Scholl SM, Mao JM. Nondaily smokers’ changes in cigarette consumption with very low-nicotine-content cigarettes: a randomized double-blind clinical trial. JAMA Psychiatry 2018; 75(10):995–1002.29902305
Shiffman S, Scholl SM, Mao JM. Very-low-nicotine-content cigarettes and dependence among non-daily smokers. Drug and Alcohol Dependence 2019;197:1–7.30743194
Shrestha SS, Davis K, Mann N, Taylor N, Nonnemaker J, Murphy-Hoefer R, Trivers KF, King BA, Babb SD, Armour BS. Cost effectiveness of the Tips From Former Smokers® campaign—U.S., 2012–2018. American Journal of Preventive Medicine 2021;60(3):406–10.33455819
Siahpush M, Shaikh RA, Robbins R, Tibbits M, Kessler AS, Soliman G, McCarthy M, Singh GK. Point-of-sale cigarette marketing and smoking-induced deprivation in smokers: results from a population-based survey. BMC Public Health 2016;16:302.27121197
Siegel M, Carol J, Jordan J, Hobart R, Schoenmarklin S, DuMelle F, Fisher PR. Preemption in tobacco control: review of an emerging public health program. JAMA: the Journal of the American Medical Association 1997;278(10):858–63.9293996
Simmons VN, Sutton SK, Medina-Ramirez P, Martinez U, Brandon KO, Byrne MM, Meade CD, Meltzer LR, Brandon TH. Self-help smoking cessation intervention for Spanish-speaking Hispanics/Latinxs in the United States: A randomized controlled trial. Cancer 2022;128(5):984–94.34679188
Singh S. Special Delivery: How Internet platforms use artificial intelligence to target and deliver ads, February 18, 2020; <https://www.newamerica.org/oti/reports/special-delivery/>; accessed: August 24, 2023.
Singh T, Agaku IT, Arrazola RA, Marynak KL, Neff LJ, Rolle IT, King BA. Exposure to advertisements and electronic cigarette use among U.S. middle and high school students. Pediatrics 2016a;137(5):e20154155.27244815
Singh T, Marynak K, Arrazola RA, Cox S, Rolle IV, King BA. Vital signs: exposure to electronic cigarette advertising among middle school and high school students—United States, 2014. Morbidity and Mortality Weekly Report 2016b;64(52):1403–8.26741522
Skeer M, George S, Hamilton WL, Cheng DM, Siegel M. Town-level characteristics and smoking policy adoption in Massachusetts: are local restaurant smoking regulations fostering disparities in health protection? American Journal of Public Health 2004;94(2):286–92.14759944
Skopec L, Long SK. Lesbian, gay, and bisexual adults making gains in health insurance and access to care. Health Affairs 2015;34(10):1769–73.26438755
Slater JS, Nelson CL, Parks MJ, Ebbert JO. Connecting low-income smokers to tobacco treatment services. Addictive Behaviors 2016;52:108–14.26489597
Slopen N, Dutra LM, Williams DR, Mujahid MS, Lewis TT, Bennett GG, Ryff CD, Albert MA. Psychosocial stressors and cigarette smoking among African American adults in midlife. Nicotine & Tobacco Research 2012;14(10):1161–9.22367977
Slopen N, Kontos EZ, Ryff CD, Ayanian JZ, Albert MA, Williams DR. Psychosocial stress and cigarette smoking persistence, cessation, and relapse over 9–10 years: a prospective study of middle-aged adults in the United States. Cancer Causes & Control 2013;24(10):1849–63.23860953
Smith CE, Hill SE, Amos A. Impact of population tobacco control interventions on socioeconomic inequalities in smoking: a systematic review and appraisal of future research directions. Tobacco Control 2020;30(e2):e87–e95.32994297
Smith DM, Christensen C, van Bemmel D, Borek N, Ambrose B, Erives G, Niaura R, Edwards KC, Stanton CA, Blount BC, . Exposure to nicotine and toxicants among dual users of tobacco cigarettes and e-cigarettes: Population Assessment of Tobacco and Health (PATH) Study, 2013–2014. Nicotine & Tobacco Research 2021a;23(5):790–7.33590857
Smith DM, Hyland AJ, Rivard C, Bednarczyk EM, Brody PM, Marshall JR. Tobacco sales in pharmacies: a survey of attitudes, knowledge and beliefs of pharmacists employed in student experiential and other worksites in Western New York. BMC Research Notes 2012;5:413.22867129
Smith EA, McDaniel PA, Hiilamo H, Malone RE. Policy coherence, integration, and proportionality in tobacco control: Should tobacco sales be limited to government outlets? Journal of Public Health Policy 2017;38(3):345–58.28432335
Smith SS, Rouse LM, Caskey M, Fossum J, Strickland R, Culhane JK, Waukau J. Culturally-tailored smoking cessation for adult American Indian smokers: a clinical trial. The Counseling Psychologist 2014;42(6):852–86.26973352
Smith TT, Nahhas GJ, Borland R, Cho YJ, Chung-Hall J, Fairman RT, Fong GT, McNeill A, Popova L, Thrasher JF, . Which tobacco control policies do smokers support? Findings from the International Tobacco Control Four Country Smoking and Vaping Survey. Preventive Medicine 2021b;149:106600.33957152
Snyder K, Vick JH, King BA. Smoke-free multiunit housing: a review of the scientific literature. Tobacco Control 2016;25(1):9–20.25566811
Sobel L, Ranji U, Pestaina K, Dawson L, Cubanski J. Explaining litigation challenging the ACA’s preventive services requirements: Braidwood Management Inc. v. Becerra, May 15, 2023; <https://www.kff.org/womens-health-policy/issue-brief/explaining-litigation-challenging-the-acas-preventive-services-requirements-braidwood-management-inc-v-becerra/>; accessed: June 16, 2023.
Social Security Act of 1992, § 1848(o), 42 U.S. Code § 1395–4 (1992).
Social Security Act of 1996, § 1886(n)(3)(A), 42 U.S. Code § 1395ww (1996).
Sommers BD, Gunja MZ, Finegold K, Musco T. Changes in self-reported insurance coverage, access to care, and health under the Affordable Care Act. JAMA: the Journal of the American Medical Association 2015;314(4):366–74.26219054
Son Y, Giovenco DP, Delnevo C, Khlystov A, Samburova V, Meng Q. Indoor air quality and passive e-cigarette aerosol exposures in vape-shops. Nicotine & Tobacco Research 2020;22(10):1772–9.32445475
Song AV, Dutra LM, Neilands TB, Glantz SA. Association of smoke-free laws with lower percentages of new and current smokers among adolescents and young adults: an 11-year longitudinal study. JAMA Pediatrics 2015;169(9):e152285.26348866
Song AV, Morrell HE, Cornell JL, Ramos ME, Biehl M, Kropp RY, Halpern-Felsher BL. Perceptions of smoking-related risks and benefits as predictors of adolescent smoking initiation. American Journal of Public Health 2009;99(3):487–92.19106420
Sorensen G. Organized labor and worksite smoking policies: results of a survey of labor leaders. New Solutions 1996;6(4):57–60.22909810
Sorensen G, Barbeau E, Hunt MK, Emmons K. Reducing social disparities in tobacco use: a social contextual model for reducing tobacco use among blue-collar workers. American Journal of Public Health 2004;94(2):230–9.14759932
Sorensen G, Barbeau E, Stoddard A, Hunt MK, Kaphingst K, Wallace L. Promoting behavior change among working-class, multi-ethnic workers: results of the Healthy Directions Small Business Study. American Journal of Public Health 2005;95(8):1389–95.16006422
Sorensen G, Barbeau EM, Stoddard AM, Hunt MK, Goldman R, Smith A, Brennan AA, Wallace L. Tools for health: the efficacy of a tailored intervention targeted for construction laborers. Cancer Causes Control 2007;18(1):51–9.17186421
Sorensen G, Landsbergis P, Hammer L, Amick B, Linnan L, Yancey A, Welch L, Goetzel R, Flannery K, Pratt C. Preventing chronic disease at the workplace: a workshop report and recommendations. American Journal of Public Health 2011;101(Suppl 1):S196–S207.21778485
Sorensen G, Stoddard A, Hunt MK, Hebert JR, Ockene JK, Avrunin JS, Himmelstein J, Hammond SK. The effects of a health promotion-health protection intervention on behavior change: the WellWorks Study. American Journal of Public Health 1998;88(11):1685–90.9807537
Sorensen G, Stoddard A, LaMontagne A, Emmons K, Hunt M, Youngstrom R, McLellan D, Christiani D. A comprehensive worksite cancer prevention intervention: behavior change results from a randomized controlled trial in manufacturing worksites (United States). Cancer Causes and Control 2002;13(6):493–502.12195637
Stanton CA, Papandonatos GD, Shuter J, Bicki A, Lloyd-Richardson EE, de Dios MA, Morrow KM, Makgoeng SB, Tashima KT, Niaura RS. Outcomes of a tailored intervention for cigarette smoking cessation among Latinos living with HIV/AIDS. Nicotine & Tobacco Research 2015;17(8):975–82.26180222
Stein A, Suttie J, Baker L, Agans R, Xue W, Bowling JM. Predictors of smoke-free policies in affordable multiunit housing, North Carolina, 2013. Preventing Chronic Disease 2015;12:E73.25974143
Stillman FA, Becker DM, Swank RT, Hantula D, Moses H, Glantz S, Waranch HR. Ending smoking at the Johns Hopkins Medical Institutions. An evaluation of smoking prevalence and indoor air pollution. JAMA: the Journal of the American Medical Association 1990;264(12):1565–9.2395198
Stotts AL, Northrup TF, Green C, Suchting R, Hovell MF, Khan A, Villarreal YR, Schmitz JM, Velasquez MM, Hammond SK, . Reducing tobacco smoke exposure in high-risk infants: a randomized, controlled trial. Journal of Pediatrics 2020;218:35–41.e1.31870605
Sulzberger AG. Hospitals shift smoking bans to smoker ban. The New York Times, February 10, 2011; <https://www.nytimes.com/2011/02/11/us/11smoking.html?_r=1&ref=health>; accessed: June 16, 2023.
Sykes JB, Vanatko N. Federal Preemption: A Legal Primer. Washington (DC): Congressional Research Service, 2019.
Tabuchi T, Iso H, Brunner E. Tobacco control measures to reduce socioeconomic inequality in smoking: the necessity, time-course perspective, and future implications. Journal of Epidemiology 2018;28(4):170–5.29151476
Tan ASL, Young-Wolff KC, Carter-Harris L, Salloum RG, Banerjee SC. Disparities in the receipt of tobacco treatment counseling within the U.S. context of the Affordable Care Act and meaningful use implementation. Nicotine & Tobacco Research 2018;20(12):1474–80.29059372
Tan CE, Glantz SA. Association between smoke-free legislation and hospitalizations for cardiac, cerebrovascular, and respiratory diseases: a meta-analysis. Circulation 2012;126(18):2177–83.23109514
Tauras JA, Chaloupka FJ, Moor G, Henderson PN, Leischow SJ. Effect of the Smoke-Free Illinois Act on casino admissions and revenue. Tobacco Control 2018;27(e2):e130–e135.29351930
Tauras JA, Huang J, Chaloupka FJ. Differential impact of tobacco control policies on youth sub-populations. International Journal of Environmental Research and Public Health 2013;10(9):4306–22.24036487
Thalheimer R, Ali M. The demand for casino gaming with special reference to a smoking ban. Economic Inquiry 2008;(46):273–82.
The Community Guide. Tobacco use: interventions to increase the unit price for tobacco products, November 2012; <https://www.thecommunityguide.org/findings/tobacco-use-interventions-increase-unit-price-tobacco.html>; accessed: June 19, 2023.
The Florida Senate. 2021 Florida statutes (including 2021B session). Section 569.0025 Preemption, 2021; <https://www.flsenate.gov/laws/statutes/2021/569.0025>; accessed: July 8, 2022.
The Joint Commission. Tobacco treatment, 2012; <https://www.jointcommission.org/measurement/measures/tobacco-treatment/>; accessed: April 28, 2020.
The Joint Commission. New Requirements to Reduce Health Care Disparities, June 30, 2022; <https://www.jointcommission.org/-/media/tjc/documents/standards/r3-reports/r3_disparities_july2022-6-20-2022.pdf>; accessed: June 16, 2023.
Thomas RE, McLellan J, Perera R. School-based programmes for preventing smoking. Evidence-Based Child Health: A Cochrane Review Journal 2013;8(5):1616–2040.
Thomas RE, McLellan J, Perera R. Effectiveness of school-based smoking prevention curricula: systematic review and meta-analysis. BMJ Open 2015;5(3):e006976.
Thorndike AN, Biener L, Rigotti NA. Effect on smoking cessation of switching nicotine replacement therapy to over-the-counter status. American Journal of Public Health 2002;92(3):437–42.11867326
Thorpe LE, Anastasiou E, Wyka K, Tovar A, Gill E, Rule A, Elbel B, Kaplan SA, Jiang N, Gordon T, . Evaluation of secondhand smoke exposure in New York City public housing after implementation of the 2018 Federal Smoke-Free Housing Policy. JAMA Network Open 2020;3(11):e2024385.33151318
Thrasher JF, Carpenter MJ, Andrews JO, Gray KM, Alberg AJ, Navarro A, Friedman DB, Cummings KM. Cigarette warning label policy alternatives and smoking-related health disparities. American Journal of Preventive Medicine 2012;43(6):590–600.23159254
Tidey JW, Colby SM, Denlinger-Apte RL, Goodwin C, Cioe PA, Cassidy RN, Swift RM, Lindgren BR, Rubin N, Murphy SE, . Effects of 6-week use of very low nicotine content cigarettes in smokers with serious mental illness. Nicotine & Tobacco Research 2019;21(Suppl 1):S38–S45.31867650
Tidey JW, Davis DR, Miller ME, Pericot-Valverde I, Denlinger-Apte RL, Gaalema DE. Modeling nicotine regulation: a review of studies in smokers with mental health conditions. Preventive Medicine 2018;117:30–7.30343684
Tidey JW, Snell LM, Colby SM, Cassidy RN, Denlinger-Apte RL. Effects of very low nicotine content cigarettes on smoking across vulnerable populations. Preventive Medicine 2022;165(Pt B):107099.35642796
Timberlake DS, Wu J, Al-Delaimy WK. Tribal casinos in California: the last vestige of indoor smoking. BMC Public Health 2012;12:144.22364487
Tindle HA, Daigh R, Reddy VK, Bailey LA, Ochs JA, Maness MH, Davis EM, Schulze AE, Powers KM, Ylioja TE, . eReferral between hospitals and quitlines: an emerging tobacco control strategy. American Journal of Preventive Medicine 2016;51(4):522–6.27476383
Tobacco Control Enforcement for Racial Equity. Decriminalizing Commercial Tobacco: Addressing Systemic Racism in the Enforcement of Commercial Tobacco Control, January 2021; <https://countertobacco.org/wp-content/uploads/2021/02/TobaccoControlEnforcementforRacialEquity_FINAL_20210129-2.pdf>; accessed: August 10, 2023.
Tobacco Control Legal Consortium. Federal Regulation of Tobacco: Impact on State and Local Authority. St. Paul (MN): Tobacco Control Legal Consortium, 2009.
Tobacco Control Legal Consortium. Cigarette Minimum Price Laws, 2011; <https://publichealthlawcenter.org/sites/default/files/resources/tclc-guide-cigminimumpricelaws-2011.pdf>; accessed: May 18, 2023.
Tobacco Control Legal Consortium. Preemption: The Biggest Challenge to Tobacco Control, 2014a; <https://publichealthlawcenter.org/sites/default/files/resources/tclc-fs-preemption-tobacco-control-challenge-2014.pdf>; accessed: August 9, 2023.
Tobacco Control Legal Consortium. Prohibiting the Sale of Tobacco Products in Pharmacies. St. Paul (MN): Tobacco Control Legal Consortium, 2014b.
Tobacco Control Legal Consortium and Public Health and Tobacco Policy Center. U.S. E-Cigarette Regulation: A 50-State Review, 2018; <http://www.publichealthlawcenter.org/sites/default/files/E-Cigarette-Legal-Landscape-50-State-Review-March-2018.pdf>; accessed: April 20, 2020.
Tobacco Products Scientific Advisory Committee. Menthol Cigarettes and Public Health: Review of the Scientific Evidence and Recommendations. Washington (DC): U.S. Food and Drug Administration, 2011.
Tomson T, Helgason AR, Gilljam H. Quitline in smoking cessation: a cost-effectiveness analysis. International Journal of Technology Assessment in Health Care 2004;20(4):469–74.15609797
Tong EK, Saw A, Fung LC, Li CS, Liu Y, Tsoh JY. Impact of a smoke-free-living educational intervention for smokers and household nonsmokers: a randomized trial of Chinese American pairs. Cancer 2018a;124(Suppl 7): 1590–1598.29578595
Tong EK, Stewart SL, Schillinger D, Vijayaraghavan M, Dove MS, Epperson AE, Vela C, Kratochvil S, Anderson CM, Kirby CA, . The Medi-Cal Incentives to Quit Smoking Project: impact of statewide outreach through health channels. American Journal of Preventive Medicine 2018b;55(6 Suppl 2):S159–S169.30454670
Tong EK, Tang H, Tsoh J, Wong C, Chen MS Jr. Smoke-free policies among Asian-American women: comparisons by education status. American Journal of Preventive Medicine 2009;37(2 Suppl):S144–S150.19591754
Trapl E, Anesetti-Rothermel A, Pike Moore S, Gittleman H. Association between school-based tobacco retailer exposures and young adolescent cigarette, cigar and e-cigarette use. Tobacco Control 2021a;30(e2):e104–e110.32817573
Trapl ES, VanFrank B, Kava CM, Trinh V, Land SR, Williams RS, Frost E, Babb S. Smoking and cessation behaviors in patients at federally funded health centers—United States, 2014. Drug and Alcohol Dependence 2021b;55(6 Suppl 2):S214–S221.
Trickett EJ, Moos RH. Social environment of junior high and high school classrooms. Journal of Educational Psychology 1973;65(1):93–102.
Trumbo CW, Harper R. Use and perception of electronic cigarettes among college students. Journal of American College Health 2013;61(3):149–55.25158012
Truth Initiative. How the Tobacco-Free College Program has helped campuses protect 1 million people, September 27, 2019a; <https://truthinitiative.org/research-resources/tobacco-prevention-efforts/how-tobacco-free-college-program-has-helped-campuses>; accessed: July 12, 2022.
Truth Initiative. Tobacco and Pharmacies. Washington (DC): Truth Initiative, 2019b.
Truth Initiative. Tobacco Nation: An Ongoing Crisis—Examining the Health and Policy Disparities of U.S. States with the Highest Smoking Rates, June 2019c; <https://truthinitiative.org/sites/default/files/media/files/2019/06/Tobacco-Nation-An-Ongoing-Crisis.pdf>; accessed: July 26, 2022.
Truth Initiative. Flavored Tobacco Policy Restrictions, March 31, 2023; <https://truthinitiative.org/sites/default/files/media/files/2023/04/Q1_2023_FINAL.pdf>; accessed: June 16, 2023.
Truth Initiative. Flavored tobacco policy resources, n.d.; <https://truthinitiative.org/our-top-issues/flavored-tobacco>; accessed: June 19, 2023.
Tsao TY, Konty KJ, Van Wye G, Barbot O, Hadler JL, Linos N, Bassett MT. Estimating potential reductions in premature mortality in New York City from raising the minimum wage to $15. American Journal of Public Health 2016;106(6):1036–41.27077350
TSET Health Promotion Research Center, University of Oklahoma Health Sciences. In Their Own Words: An Analysis of Internal Tobacco Industry Documents on Interference in Oklahoma Laws, March 2020; <https://healthpromotionresearch.org/Portals/1005a/Assets/Documents/Policy/2022%20In%20Their%20Own%20Words%20-%20An%20Analysis%20of%20Internal%20Tobacco%20Industry%20Documents%20on%20Interference%20in%20Oklahoma%20Laws%20(HPRC).pdf?ver=2022-08-23-101513-147>; accessed: February 26, 2024.
Tsoh J. University of California–San Francisco, personal communication, July 11, 2021.
Tsoh J, Burke N, Gildengorin G, Le K, Wong C, Kim J, McPhee S, Nguyen T. Promoting smoking cessation among Vietnamese Americans using a family-based lay health worker intervention: a cluster randomized controlled trial. Paper presented at the 23rd Annual Meeting of the Society for Research on Nicotine and Tobacco; March 8–11, 2017; Florence (Italy).
Tsoh JY, Burke NJ, Gildengorin G, Wong C, Le K, Nguyen A, Chan JL, Sun A, McPhee SJ, Nguyen TT. A social network family-focused intervention to promote smoking cessation in Chinese and Vietnamese American male smokers: a feasibility study. Nicotine & Tobacco Research 2015;17(8):1029–38.26180229
Tucker-Seeley RD, Bezold CP, James P, Miller M, Wallington SF. Retail pharmacy policy to end the sale of tobacco products: what is the impact on disparity in neighborhood density of tobacco outlets? Cancer Epidemiology, Biomarkers & Prevention 2016;25(9):1305–10.
Tynan MA, Holmes CB, Promoff G, Hallett C, Hopkins M, Frick B. State and local comprehensive smoke-free laws for worksites, restaurants, and bars—United States, 2015. Morbidity and Mortality Weekly Report 2016;65(24):623–6.27337212
Tynan MA, Wang TW, Marynak KL, Lemos P, Babb SD. Attitudes toward smoke-free casino policies among U.S. adults, 2017. Public Health Reports 2019;134(3):234–40.30895873
U.S. Bureau of Labor Statistics. Number of hospitals and hospital employment in each state in 2019, TED: The Economics Daily, April 6, 2020a; <https://www.bls.gov/opub/ted/2020/number-of-hospitals-and-hospital-employment-in-each-state-in-2019.htm#:~:text=For%20the%20entire%20nation%2C%20there%20were%2013%2C944%20hospitals,ratios%20were%20New%20York%2C%20Oregon%2C%20and%20Rhode%20Island>; accessed: June 21, 2023.
U.S. Bureau of Labor Statistics. Union members—2019 [news release], 2020b; <https://www.bls.gov/news.release/pdf/union2.pdf>; accessed: April 20, 2020.
U.S. Census Bureau. EC1244SLLS1—retail trade: subject series—product lines: product lines statistics by industry for the U.S. and states: 2012, 2012; <https://www.census.gov/data/tables/2012/econ/census/retail-trade.html>; accessed: April 22, 2020.
U.S. Census Bureau. Why we ask questions about … School enrollment, n.d.; <https://www.census.gov/acs/www/about/why-we-ask-each-question/school/>; accessed: August 14, 2023.
U.S. Department of Education. Tribal colleges and universities, 2020; <https://sites.ed.gov/whiaiane/tribes-tcus/tribal-colleges-and-universities/>; accessed: April 20, 2020.
U.S. Department of Health and Human Services. The Health Consequences of Smoking: Cancer and Chronic Lung Disease in the Workplace. A Report of the Surgeon General. Rockville (MD): U.S. Department of Health and Human Services, Public Health Service, Office on Smoking and Health, 1985. DHHS Publication No. (PHS) 85-50207.
U.S. Department of Health and Human Services. The Health Consequences of Involuntary Smoking: A Report of the Surgeon General. Rockville (MD): U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, Center for Health Promotion and Education, Office on Smoking and Health, 1986. DHHS Publication No. (CDC) 87-8398.
U.S. Department of Health and Human Services. Tobacco Use Among U.S. Racial/Ethnic Minority Groups—African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1998.
U.S. Department of Health and Human Services. Reducing Tobacco Use. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2000.
U.S. Department of Health and Human Services. The Health Consequences of Smoking: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2004.
U.S. Department of Health and Human Services. The Health Consequences of Involuntary Exposure to Tobacco Smoke: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, Coordinating Center for Health Promotion, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2006.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2012.
U.S. Department of Health and Human Services. The Health Consequences of Smoking—50 Years of Progress: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2014.
U.S. Department of Health and Human Services. E-Cigarette Use Among Youth and Young Adults. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2016.
U.S. Department of Health and Human Services. Smoking Cessation. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2020.
U.S. Department of Housing and Urban Development. Change is in the Air. An Action Guide for Establishing Smoke-Free Public Housing and Multifamily Properties. Washington (DC): U.S. Department of Housing and Urban Development, Office of Lead Hazard Control and Healthy Homes, 2014.
U.S. Department of Housing and Urban Development, Office of Healthy Homes and Lead Hazard Control. Smoke-free housing, 2016; <https://portal.hud.gov/hudportal/HUD?src=/program_offices/healthy_homes/smokefree>; accessed: April 20, 2020.
U.S. Department of Labor. Fact sheet #17I: blue-collar workers and the Part 541 exemptions under the Fair Labor Standards Act (FLSA), September 2019; <https://www.dol.gov/agencies/whd/fact-sheets/17i-overtime-blue-collar>; accessed: June 16, 2023.
U.S. Food and Drug Administration. Preliminary Scientific Evaluation of the Possible Public Health Effects of Menthol Versus Nonmenthol Cigarettes, 2013; <https://www.fda.gov/media/86497/download>; accessed: February 19, 2019.
U.S. Food and Drug Administration. Deeming Tobacco Products To Be Subject to the Federal Food, Drug, and Cosmetic Act, as Amended by the Family Smoking Prevention and Tobacco Control Act; restrictions on the sale and distribution of tobacco products and required warning statements for tobacco products. Final rule. Federal Register 2016;81:28973–9106.27192730
U.S. Food and Drug Administration. Family Smoking Prevention and Tobacco Control Act. Silver Spring (MD): U.S. Food and Drug Administration, 2018a.
U.S. Food and Drug Administration. Fresh Empire campaign, 2018b; <https://www.fda.gov/tobacco-products/public-health-education-campaigns/free-life-campaign>; accessed: February 19, 2019.
U.S. Food and Drug Administration. Illicit Trade in Tobacco Products After Implementation of an FDA Product Standard, March 15, 2018c; <https://www.fda.gov/files/tobacco%20products/published/Illicit-Trade-in-Tobacco-Products-After-Implementation-of-an-FDA-Product-Standard.pdf>; accessed: June 20, 2023.
U.S. Food and Drug Administration. About the Center for Tobacco Products (CTP), May 16, 2019; <https://www.fda.gov/tobaccoproducts/aboutctp/default.htm>; accessed: April 28, 2020.
U.S. Food and Drug Administration. FDA finalizes enforcement policy on unauthorized flavored cartridge-based e-cigarettes that appeal to children, including fruit and mint [press release], January 2, 2020; <https://www.fda.gov/news-events/press-announcements/fda-finalizes-enforcement-policy-unauthorized-flavored-cartridge-based-e-cigarettes-appeal-children>; accessed: July 10, 2022.
U.S. Food and Drug Administration. FDA proposes rules prohibiting menthol cigarettes and flavored cigars to prevent youth initiation, significantly reduce tobacco-related disease and death [press release], April 28, 2022a; <https://www.fda.gov/news-events/press-announcements/fda-proposes-rules-prohibiting-menthol-cigarettes-and-flavored-cigars-prevent-youth-initiation>; accessed: May 24, 2022.
U.S. Food and Drug Administration. Next Legends Campaign, 2022b; <https://www.fda.gov/tobacco-products/public-health-education-campaigns/next-legends-campaign>; accessed: May 19, 2023.
U.S. Food and Drug Administration. Review of Studies Assessing the Potential Impact of Prohibiting Menthol as a Characterizing Flavor in Cigarettes. Rockville (MD): U.S. Food and Drug Administration, 2022c.
U.S. Food and Drug Administration. This Free Life campaign, March 11, 2022d; <https://www.fda.gov/TobaccoProducts/PublicHealthEducation/PublicEducationCampaigns/ThisFreeLifeCampaign/default.htm>; accessed: August 22, 2023.
U.S. Food and Drug Administration. Regulation and enforcement of non-tobacco nicotine (NTN) products, June 9, 2023; <https://www.fda.gov/tobacco-products/products-ingredients-components/regulation-and-enforcement-non-tobacco-nicotine-ntn-products>; accessed: June 26, 2023.
U.S. Food and Drug Administration. Every Try Counts campaign, n.d.a; <https://www.fda.gov/tobacco-products/public-health-education-campaigns/every-try-counts-campaign>; accessed: July 30, 2022.
U.S. Food and Drug Administration. Premarket tobacco product marketing granted orders, n.d.b; <https://www.fda.gov/tobacco-products/premarket-tobacco-product-applications/premarket-tobacco-product-marketing-granted-orders>; accessed: July 10, 2022.
U.S. Food and Drug Administration. Tobacco user fees, n.d.c; <https://www.fda.gov/tobacco-products/manufacturing/tobacco-user-fees>; accessed: July 6, 2022.
Ulucanlar S, Fooks GJ, Gilmore AB. The policy dystopia model: an interpretive analysis of tobacco industry political activity. PLoS Medicine 2016;13(9):e1002125.27649386
University of California–Berkeley, Labor Occupational Health Program. The whole worker: guidelines for integrating occupational health and safety with workplace wellness programs, 2016; <https://www.dir.ca.gov/chswc/WOSHTEP/Publications/WOSHTEP_TheWholeWorker.pdf>; accessed: April 21, 2020.
University of Massachusetts–Lowell. Healthy workplace participatory program, 2017; <https://www.uml.edu/Research/CPH-NEW/Healthy-Work-Participatory-Program/>; accessed: April 21, 2020.
Valdez ES, Skobic I, Valdez L, D O G, Korchmaros J, Stevens S, Sabo S, Carvajal S. Youth participatory action research for youth substance use prevention: a systematic review. Substance Use & Misuse 2020;55(2):314–28.31596160
Vallone DM, Allen JA, Xiao H. Is socioeconomic status associated with awareness of and receptivity to the truth campaign? Drug and Alcohol Dependence 2009;104(Suppl 1):S115–S120.19442459
Vallone DM, Cantrell J, Bennett M, Smith A, Rath JM, Xiao H, Greenberg M, Hair EC. Evidence of the impact of the truth FinishIt campaign. Nicotine & Tobacco Research 2018;20(5):543–51.28575421
Vallone DM, Duke JC, Cullen J, McCausland KL, Allen JA. Evaluation of EX: a national mass media smoking cessation campaign. American Journal of Public Health 2011a;101(2):302–9.21164094
Vallone DM, Ilakkuvan V, Xiao H, Cantrell J, Rath J, Hair E. Contextual influences and campaign awareness among young adults: evidence from the national Truth^®^ campaign. Behavioral Medicine 2015;41(3):155–63.26332933
Vallone DM, Niederdeppe J, Richardson AK, Patwardhan P, Niaura R, Cullen J. A national mass media smoking cessation campaign: effects by race/ethnicity and education. American Journal of Health Promotion 2011b;25(5 Suppl):S38–S50.21510785
van den Brand FA, Nagelhout GE, Reda AA, Kotz D, Evers SMAA, van Schayck CP. Healthcare financing systems for increasing the use of tobacco dependence treatment. Cochrane Database of Systematic Reviews 2012, Issue 9. Art. No.: CD004305. DOI: 10.1002/14651858.CD004305.pub5.
Venkataramani AS, Cook E, O’Brien RL, Kawachi I, Jena AB, Tsai AC. College affirmative action bans and smoking and alcohol use among underrepresented minority adolescents in the United States: a difference-in-differences study. PLoS Medicine 2019; 16(6):e1002821.31211777
Verguet S, Kearns PKA, Rees VW. Questioning the regressivity of tobacco taxes: a distributional accounting impact model of increased tobacco taxation. Tobacco Control 2021;30(3):245–57.32576701
Vickerman KA, Schauer GL, Malarcher AM, Zhang L, Mowery P, Nash CM. Quitline use and outcomes among callers with and without mental health conditions: a 7-month follow-up evaluation in three states. BioMed Research International 2015a;2015:817298.26273647
Vickerman KA, Zhang L, Malarcher A, Mowery P, Nash C. Cessation outcomes among quitline callers in three states during a national tobacco education campaign. Preventing Chronic Disease 2015b;12:E110.26182145
Vidrine JI, Shete S, Cao Y, Greisinger A, Harmonson P, Sharp B, Miles L, Zbikowski SM, Wetter DW. Ask-Advise-Connect: a new approach to smoking treatment delivery in health care settings. JAMA Internal Medicine 2013;173(6):458–64.23440173
Vidrine JI, Spears CA, Heppner WL, Reitzel LR, Marcus MT, Cinciripini PM, Waters AJ, Li Y, Nguyen NT, Cao Y, . Efficacy of mindfulness-based addiction treatment (MBAT) for smoking cessation and lapse recovery: A randomized clinical trial. Journal of Consulting and Clinical Psychology 2016;84(9):824–38.27213492
Vijayaraghavan M, Benmarnhia T, Pierce JP, White MM, Kempster J, Shi Y, Trinidad DR, Messer K. Income disparities in smoking cessation and the diffusion of smokefree homes among U.S. smokers: results from two longitudinal surveys. PLoS One 2018a;13(7):e0201467.30052671
Vijayaraghavan M, Dove MS, Stewart SL, Cummins SE, Schillinger D, Kohatsu ND, Tong EK. Racial/ethnic differences in the response to incentives for quitline engagement. American Journal of Preventive Medicine 2018b;55(6 Suppl 2):S186–S195.30454673
Vijayaraghavan M, Schroeder SA, Kushel M. The effectiveness of tobacco control policies on vulnerable populations in the U.S.A.: a review. Postgraduate Medical Journal 2016;92(1093):670–6.27660283
Villanti AC, Byron MJ, Mercincavage M, Pacek LR. Misperceptions of nicotine and nicotine reduction: the importance of public education to maximize the benefits of a nicotine reduction standard. Nicotine & Tobacco Research 2019a;21(Suppl 1):S88–S90.31867645
Villanti AC, Johnson AL, Glasser AM, Rose SW, Ambrose BK, Conway KP, Cummings KM, Stanton CA, Edwards KC, Delnevo CD, . Association of flavored tobacco use with tobacco initiation and subsequent use among U.S. youth and adults, 2013–2015. JAMA Network Open 2019b;2(10):e1913804.31642927
Villanti AC, Johnson AL, Halenar MJ, Sharma E, Cummings KM, Stanton CA, Delnevo CD, Wackowski OA, Bansal-Travers M, Pearson JL, . Menthol and mint cigarettes and cigars: initiation and progression in youth, young adults and adults in Waves 1–4 of the PATH Study, 2013–2017. Nicotine & Tobacco Research 2021;23(8):1318–26.33159209
Villanti AC, Mowery PD, Delnevo CD, Niaura RS, Abrams DB, Giovino GA. Changes in the prevalence and correlates of menthol cigarette use in the U.S.A., 2004–2014. Tobacco Control 2016;25(Suppl 2):ii14–ii20.27729565
Vogel EA, Ramo DE, Meacham MC, Prochaska JJ, Delucchi KL, Humfleet GL. The Put It Out Project (POP) Facebook intervention for young sexual and gender minority smokers: outcomes of a pilot, randomized, controlled trial. Nicotine & Tobacco Research 2020;22(9):1614–21.31562765
Vogel EA, Thrul J, Humfleet GL, Delucchi KL, Ramo DE. Smoking cessation intervention trial outcomes for sexual and gender minority young adults. Health Psychology 2019;38(1):12–20.30489104
Voigt K. Ethical concerns in tobacco control nonsmoker and “nonnicotine” hiring policies: the implications of employment restrictions for tobacco control. American Journal of Public Health 2012;102(11):2013–8.22994176
Volpp KG, Troxel AB, Pauly MV, Glick HA, Puig A, Asch DA, Galvin R, Zhu J, Wan F, DeGuzman J, . A randomized, controlled trial of financial incentives for smoking cessation. New England Journal of Medicine 2009;360(7):699–709.19213683
von Thiele Schwarz U, Augustsson H, Hasson H, Stenfors-Hayes T. Promoting employee health by integrating health protection, health promotion, and continuous improvement: a longitudinal quasi-experimental intervention study. Journal of Occupational and Environmental Medicine 2015;57(2):217–25.25654524
Vu M, Escoffery C, Srivanjarean Y, Do E, Berg CJ. Acculturation and exposure to secondhand smoke in the home among Vietnamese immigrants in metropolitan Atlanta. Journal of Immigrant and Minority Health 2020;22(3):580–7.31154544
Wackowski OA, Evans KR, Harrell MB, Loukas A, Lewis MJ, Delnevo CD, Perry CL. In their own words: young adults’ menthol cigarette initiation, perceptions, experiences and regulation perspectives. Nicotine & Tobacco Research 2018;20(9):1076–84.28339669
Wagner DE, Fernandez P, Jordan JW, Saggese DJ. Freedom from chew: using social branding to reduce chewing tobacco use among country peer crowd teens. Health Education & Behavior 2018;46(2):286–94.30353748
Wagoner KG, Song EY, King JL, Egan KL, Debinski B, Wolfson M, Spangler J, Sutfin EL. Availability and placement of electronic nicotine delivery systems at the point-of-sale. Nicotine & Tobacco Research 2018;20(8):1020–4.29059443
Walton K, Gentzke AS, Murphy-Hoefer R, Kenemer B, Neff LJ. Exposure to secondhand smoke in homes and vehicles among U.S. youths, United States, 2011–2019. Preventing Chronic Disease 2020;17:E103.32915130
Wang L, Lu B, Wewers ME, Foraker RE, Xie MY, Ferketich AK. Are retailers compliant with zoning regulations that ban tobacco sales near schools in Changsha, China? Tobacco Control 2017;26(4):446–51.27457789
Wang TW, Agaku IT, Marynak KL, King BA. Attitudes toward prohibiting tobacco sales in pharmacy stores among U.S. adults. American Journal of Preventive Medicine 2016;51(6):1038–43.27593419
Wang TW, Lemos PR, McNabb S, King BA. Attitudes toward smoke-free public housing among U.S. adults. American Journal of Preventive Medicine 2018a;54(1):113–8.29153476
Wang TW, Tynan MA, Hallett C, Walpert L, Hopkins M, Konter D, King BA. Smoke-free and tobacco-free policies in colleges and universities—United States and territories, 2017. Morbidity and Mortality Weekly Report 2018b;67(24):686–9.29927904
Wang Y, Duan Z, Emery SL, Kim Y, Chaloupka FJ, Huang J. The association between e-cigarette price and TV advertising and the sales of smokeless tobacco products in the U.S.A. International Journal of Environmental Research and Public Health 2021;18(13):6795.34202723
Webb Hooper M, Antoni MH, Okuyemi K, Dietz NA, Resnicow K. Randomized controlled trial of group-based culturally specific cognitive behavioral therapy among African American smokers. Nicotine & Tobacco Research 2017a;19(3):333–41.27613941
Webb Hooper M, Baker EA, Robinson RG. Efficacy of a DVD-based smoking cessation intervention for African Americans. Nicotine & Tobacco Research 2014;16(10):1327–35.24838844
Webb Hooper M, Carpenter KM, Salmon EE. Web-based tobacco cessation interventions and digital inequality across U.S. racial/ethnic groups. Ethnicity & Disease 2019;29(3):495–504.31367170
Webb Hooper M, Miller DB, Saldivar E, Mitchell C, Johnson L, Burns M, Huang MC. Randomized controlled trial testing a video-text tobacco cessation intervention among economically disadvantaged African American adults. Psychology of Addictive Behaviors 2021;35(7):769–77.34647777
Webb Hooper M, Payne M, Parkinson KA. Tobacco cessation pharmacotherapy use among racial/ethnic minorities in the United States: Considerations for primary care. Family Medicine and Community Health 2017b;5(3):193–203.
Webb Hooper M, Smiley SL. Comparison of e-cigarette use among menthol and non-menthol smokers: findings from a community based sample. Ethnicity & Disease 2018;28(3):153–60.30038476
Webb MS. Does one size fit all African American smokers? The moderating role of acculturation in culturally specific interventions. Psychology of Addictive Behaviors 2008a;22(4):592–6.19071987
Webb MS. Treating tobacco dependence among African Americans: a meta-analytic review. Health Psychology 2008b;27(3):S271–S282.18979980
Webb MS. Culturally specific interventions for African American smokers: an efficacy experiment. Journal of the National Medical Association 2009;101(9):927–35.19806851
Webb MS, de Ybarra DR, Baker EA, Reis IM, Carey MP. Cognitive-behavioral therapy to promote smoking cessation among African American smokers: a randomized clinical trial. Journal of Consulting and Clinical Psychology 2010a;78(1):24–33.20099947
Webb MS, Rodriguez-Esquivel D, Baker EA. Smoking cessation interventions among Hispanics in the United States: a systematic review and mini meta-analysis. American Journal of Health Promotion 2010b;25(2):109–18.21039291
Weinberger AH, Giovenco DP, Zhu J, Lee J, Kashan RS, Goodwin RD. Racial/ethnic differences in daily, non-daily, and menthol cigarette use and smoking quit ratios in the United States: 2002 to 2016. Preventive Medicine 2019;125:32–9.31004620
Wetter DW, Mazas C, Daza P, Nguyen L, Fouladi RT, Li Y, Cofta-Woerpel L. Reaching and treating Spanish-speaking smokers through the National Cancer Institute’s Cancer Information Service. A randomized controlled trial. Cancer 2007;109(2 Suppl):S406–S413.
Wheeler DC, Do EK, Hayes RB, Hughes C, Fuemmeler BF. Evaluation of neighborhood deprivation and store characteristics in relation to tobacco retail outlet sales violations. PLoS One 2021;16(7):e0254443.34270555
WHO Study Group on Tobacco Product Regulation. WHO Study Group on Tobacco Product Regulation: Report on the Scientific Basis of Tobacco Product Regulation: Eighth Report of a WHO Study Group. Geneva (Switzerland): World Health Organization, 2021. WHO Technical Report Series No. 1029.
Wiehe SE, Garrison MM, Christakis DA, Ebel BE, Rivara FP. A systematic review of school-based smoking prevention trials with long-term follow-up. Journal of Adolescent Health 2005;36(3):162–9.
Williams RS, Stollings JH, Bundy L, Haardorfer R, Kreuter MW, Mullen PD, Hovell M, Morris M, Kegler MC. A minimal intervention to promote smokefree homes among 2-1-1 Callers: North Carolina randomized effectiveness trial. PLoS One 2016; 11(11):e0165086.27806060
Williams SC, Hafner JM, Morton DJ, Holm AL, Milberger SM, Koss RG, Loeb JM. The adoption of smoke-free hospital campuses in the United States. Tobacco Control 2009;18(6):451–8.19700437
Williamson A, Antonisse L, Tolbert J, Garfield R. ACA coverage expansions and low-income workers, 2016; <https://www.kff.org/report-section/aca-coverage-expansions-and-low-income-workers-issue-brief/>; accessed: April 21, 2020.
Wilson KM, Klein JD, Blumkin AK, Gottlieb M, Winickoff JP. Tobacco-smoke exposure in children who live in multiunit housing. Pediatrics 2011;127(1):85–92.21149434
Wilson KM, Torok MR, McMillen RC, Klein JD, Levy DE, Winickoff JP. Tobacco-smoke incursions and satisfaction among residents with children in multiunit housing, United States, 2013. Public Health Reports 2017;132(6):637–45.28977766
Wilson SM, Newins AR, Medenblik AM, Kimbrel NA, Dedert EA, Hicks TA, Neal LC, Beckham JC, Calhoun PS. Contingency management versus psychotherapy for prenatal smoking cessation: a meta-analysis of randomized controlled trials. Women’s Health Issues 2018;28(6):514–23.30061033
Winickoff JP, Gottlieb M, Mello MM. Regulation of smoking in public housing. New England Journal of Medicine 2010;362(24):2319–25.20554988
Witman A, Acquah J, Alva M, Hoerger T, Romaire M. Medicaid incentives for preventing chronic disease: effects of financial incentives for smoking cessation. Health Services Research 2018;53(6):5016–34.29896800
Wong SL, Epperson AE, Rogers J, Castro RJ, Jackler RK, Prochaska JJ. A multimodal assessment of tobacco use on a university campus and support for adopting a comprehensive tobacco-free policy. Preventive Medicine 2020;133:106008.32027917
World Health Organization. Jakarta Statement on Healthy Workplaces. Jakarta (Indonesia): World Health Organization, 1997.
World Health Organization. Regional Guidelines for the Development of Healthy Workplaces. Shanghai (China): World Health Organization, Western Pacific Regional Office, 1999.
World Health Organization. WHO Framework Convention on Tobacco Control, 2003; <https://fctc.who.int/publications/i/item/9241591013>; accessed: February 20, 2020.
World Health Organization. Closing the Gap in a Generation: Health Equity Through Action on the Social Determinants of Health—Final Report of the Commission on Social Determinants of Health. Geneva (Switzerland): World Health Organization, 2008; <https://www.who.int/publications/i/item/WHO-IER-CSDH-08.1>; accessed: July 6, 2022.
World Health Organization. Healthy Workplaces: A Model for Action for Employers, Workers, Policy-Makers and Practitioners, 2010; <https://www.who.int/publications/i/item/9789241599313>; accessed: April 21, 2020.
World Health Organization. Developing and Improving National Toll-Free Tobacco Quit Line Services. Geneva (Switzerland): World Health Organization, 2011.
World Health Organization. Electronic Nicotine Delivery Systems: Report by WHO. Moscow (Russian Federation): Conference of the Parties to the WHO Framework Convention on Tobacco Control, 2014.
World Health Organization. Banning Menthol in Tobacco Products: WHO Study Group on Tobacco Product Regulation (TobReg), 2016a; <https://apps.who.int/iris/bitstream/handle/10665/205928/9789241510332_eng.pdf?sequence=1>; accessed: April 21, 2020.
World Health Organization. The Health and Social Effects of Nonmedical Cannabis Use. Geneva (Switzerland): World Health Organization, 2016b.
World Health Organization. Heated tobacco products (HTPs) market monitoring information sheet, 2018; <https://apps.who.int/iris/bitstream/handle/10665/273459/WHO-NMH-PND-18.7-eng.pdf?ua=1>; accessed: April 21, 2020.
World Health Organization. WHO Report on the Global Tobacco Epidemic, 2021: Addressing New and Emerging Products. Geneva (Switzerland): World Health Organization, 2021.
World Health Organization. Tobacco taxation, n.d.; <https://www.who.int/teams/health-promotion/tobacco-control/economics/taxation>; accessed: July 12, 2022.
World Health Organization, Wolf J, Prüss-Ustün A, Ivanov I, Mugdal S, Corvalán C, Bos T, Neiraet M. Preventing Disease Through a Healthier and Safer Workplace. Geneva (Switzerland): World Health Organization, 2018.
Wray RJ, Hansen N, Ding D, Masters J. Effects of a campus-wide tobacco-free policy on tobacco attitudes, norms and behaviors among students, staff and faculty. Journal of American College Health 2020:1–12.
Wu D, Ma GX, Zhou K, Zhou D, Liu A, Poon AN. The effect of a culturally tailored smoking cessation for Chinese American smokers. Nicotine & Tobacco Research 2009;11(12):1448–57.19915080
Xu X, Alexander RL, Jr., Simpson SA, Goates S, Nonnemaker JM, Davis KC, McAfee T. A cost-effectiveness analysis of the first federally funded antismoking campaign. American Journal of Preventive Medicine 2015;48(3):318–25.25498550
Xu X, Malarcher A, O’Halloran A, Kruger J. Does every U.S. smoker bear the same cigarette tax? Addiction 2014;109(10):1741–9.24861973
Xu X, Wang X, Caraballo R. Is every smoker interested in price promotions? An evaluation of price-related discounts by cigarette brands. Journal of Public Health Management and Practice 2016;22(1):20–8.26598952
Yang TY, Berg CJ. How preemption can lead to inequity. International Journal of Environmental Research and Public Health 2022;19(17):10476.36078191
Yang Y, Lindblom EN, Salloum RG, Ward KD. The impact of a comprehensive tobacco product flavor ban in San Francisco among young adults. Addictive Behaviors Reports 2020;11:100273.32368612
Yao T, Sung H-Y, Huang J, Chu L, St Helen G, Max W. The impact of e-cigarette and cigarette prices on e-cigarette and cigarette sales in California. Preventive Medicine Reports 2020;20:101244.33240784
Yao TT, Ong MK, Max W, Keeler C, Wang YN, Yerger VB, Sung HY. Responsiveness to cigarette prices by different racial/ethnic groups of U.S. adults. Tobacco Control 2018;27(3):301–9.28747492
Yearby R. Racial disparities in health status and access to healthcare: the continuation of inequality in the United States due to structural racism. American Journal of Economics and Sociology 2018;77(3–4):1113–52.
Ylioja T, Reddy V, Ambrosino R, Davis EM, Douaihy A, Slovenkay K, Kogut V, Frenak B, Palombo K, Schulze A, . Using bioinformatics to treat hospitalized smokers: successes and challenges of a tobacco treatment service. Joint Commission Journal on Quality and Patient Safety 2017;43(12):621–32.29173282
York NL, Hahn EJ, Rayens MK, Talbert J. Community readiness for local smoke-free policy change. American Journal of Health Promotion 2008;23(2):112–20.19004161
Young-Wolff KC, Klebaner D, Campbell CI, Weisner C, Satre DD, Adams AS. Association of the Affordable Care Act with smoking and tobacco treatment utilization among adults newly enrolled in health care. Medical Care 2017;55(5):535–41.28288073
Young W, Karp S, Bialick P, Liverance C, Seder A, Berg E, Karp L. Health, secondhand smoke exposure, and smoking behavior impacts of no-smoking policies in public housing, Colorado, 2014–2015. Preventing Chronic Disease 2016;13:E148.27763830
Yuan NP, Schultz JL, Nair US, Bell ML. Predictors of tobacco cessation among American Indian/Alaska Native adults enrolled in a state quitline. Substance Use & Misuse 2020;55(3):452–9.31694464
Zanis DA, Hollm RE, Derr D, Ibrahim JK, Collins BN, Coviello D, Melochick JR. Comparing intervention strategies among rural, low SES, young adult tobacco users. American Journal of Health Behavior 2011;35(2):240–7.21204686
Zare S, Nemati M, Zheng Y. A systematic review of consumer preference for e-cigarette attributes: flavor, nicotine strength, and type. PLoS One 2018;13(3):e0194145.29543907
Zbikowski SM, Hapgood J, Smucker Barnwell S, McAfee T. Phone and web-based tobacco cessation treatment: real-world utilization patterns and outcomes for 11,000 tobacco users. Journal of Medical Internet Research 2008;10(5):e41.19017583
Zeller M. Evolving “The Real Cost” campaign to address the rising epidemic of youth e-cigarette use. American Journal of Preventive Medicine 2019;56(2 Suppl 1): S76–S78.30661529
Zhang L, Babb S, Johns M, Mann N, Thompson J, Shaikh A, Lavinghouze R, Rodes R, Malarcher A. Impact of U.S. antismoking TV ads on Spanish-language quitline calls. American Journal of Preventive Medicine 2018;55(4):480–7.30241616
Zhang L, Malarcher A, Babb S, Mann N, Davis K, Campbell K, Schauer G, Alexander R, Debrot K, Rodes R. The impact of a National Tobacco Education Campaign on state-specific quitline calls. American Journal of Health Promotion 2016a;30(5):374–81.27404646
Zhang L, Malarcher A, Mann N, Campbell K, Davis K, Anderson C, Alexander R, Rodes R. The influence of state-specific quitline numbers on call volume during a national tobacco education campaign promoting 1-800-QUIT-NOW. Nicotine & Tobacco Research 2016b;18(8):1780–5.27073208
Zhang L, Rodes R, Mann N, Thompson J, McAfee T, Murphy-Hoefer R, Frank R, Davis K, Babb S. Differences in quitline registrants’ characteristics during national radio versus television antismoking campaigns. American Journal of Preventive Medicine 2021; 3(Suppl 2):S107–S112.
Zhang L, Vickerman K, Malarcher A, Carpenter K. Changes in quitline caller characteristics during a national tobacco education campaign. Nicotine & Tobacco Research 2015a;17(9):1161–6.25561612
Zhang L, Vickerman K, Malarcher A, Mowery P. Intermediate cessation outcomes among quitline callers during a national tobacco education campaign. Nicotine & Tobacco Research 2014;16(11):1478–86.25006045
Zhang X, Martinez-Donate A, Rhoads N. Parental practices and attitudes related to smoke-free rules in homes, cars, and outdoor playgrounds in U.S. households with underage children and smokers, 2010–2011. Preventing Chronic Disease 2015b;12:E96.26086609
Zhou Z, Bohac D, Boyle RG. Continuous weeklong measurements of indoor particle levels in a Minnesota Tribal Casino Resort. BMC Public Health 2016;16(1):870.27557528
Zhu S-H, Wong S, Tang H, Shi CW, Chen MS. High quit ratio among Asian immigrants in California: implications for population tobacco cessation. Nicotine & Tobacco Research 2007;9(Suppl 3):S505–S514.17978979
Zhu S-H., Gardiner P, Cummins S, Anderson C, Wong S, Cowling D, Gamst A. Quitline utilization rates of African-American and White smokers: the California experience. American Journal of Health Promotion 2011;25(5 Suppl):S51–S58.21510787
Zhu S-H, Cummins SE, Wong S, Gamst AC, Tedeschi GJ, Reyes-Nocon J. The effects of a multilingual telephone quitline for Asian smokers: a randomized controlled trial. Journal of the National Cancer Institute 2012;104(4):299–310.22282542

1 Policy is a broad term that includes laws, regulations, rules, and organizational practices. In this chapter, references to governmental policies could encompass different mechanisms (e.g., laws or regulations) to achieve a specific goal. References to laws describe legislation enacted by a government.

2 A single estimate of the total number of hospitals and medical centers is not available. According to the Bureau of Labor Statistics (2020a), there were 13,944 hospitals in the third quarter of 2019. Also there are a total of 5,317 hospitals registered with Medicare (Centers for Medicare & Medicaid Services 2023). However, because of differences that can occur in counts when identifying a hospital site or hospital system, these numbers should not be used to calculate an overall proportion of hospitals that are smokefree.

3 A single estimate of the total number of psychiatric facilities is not available. There are a total of 609 psychiatric facilities registered with Medicare (Centers for Medicare & Medicaid Services 2023). However, because of differences that can occur in counts when identifying a hospital site or hospital system, these numbers should not be used to calculate an overall proportion of psychiatric facilities that are smokefree.

4 Meaningful Use leveraged certified EHR technology to advance multiple objectives, including improving the quality, safety, and efficiency of healthcare and reducing health disparities; engaging patients and families; improving the coordination of care; improving population and public health; and maintaining the privacy and security of patient health information (Federal Register 2010; HealthIT.gov 2019). The minimum criteria for Meaningful Use required (1) use of certified EHR technology in a meaningful manner (e.g., electronic prescribing); (2) use of certified EHR technology for electronic exchange of health information to improve healthcare quality; and (3) use of certified EHR technology to submit clinical quality measures and other measures required by USDHHS (Social Security Act of 1992 1992; Social Security Act of 1996 1996; HITECH Act 2009; Social Security Administration n.d.).

* URL was active on the access date shown in the reference entry but was no longer active when this Surgeon General’s report was released.