# Chapter 5 Tobacco Industry Influences on Tobacco-Related Health Disparities

## Introduction

The tobacco industry strongly influences the promotion and use of tobacco products. Tobacco Control Monograph 19, which was released by the National Cancer Institute (NCI) in 2008, concluded that “[t]he total weight of evidence—from multiple types of studies, conducted by investigators from different disciplines, and using data from many countries—demonstrates a causal relationship between tobacco advertising and promotion and increased tobacco use” (NCI 2008, p. 11). The subsequent 2014 Surgeon General’s report, titled The Health Consequences of Smoking—50 Years of Progress, also concluded that there is a causal relationship between tobacco marketing and tobacco use among youth and young adults: “The evidence is sufficient to conclude that advertising and promotional activities by the tobacco companies cause the onset and continuation of smoking among adolescents and young adults” (U.S. Department of Health and Human Services [USDHHS] 2014, p. 12).

As shown in Figures 1.1 (in Chapter 1) and 4.1 (in Chapter 4), this report conceptualizes the influence of the tobacco industry as separate from, but intersecting with, social and environmental influences that affect individual tobacco use and tobacco-related health disparities. This chapter also draws on the Host-Agent-Vector-Environment (HAVE) model to examine influences on tobacco use, with a particular focus on influences from the tobacco industry—or the “vector” (Figure 5.1) (Giovino et al. 2009; Samet and Wipfli 2013; Hyland et al. 2017; McKee and Stuckler 2018; Garcia-Cazarin et al. 2020). The HAVE model, which is based on an epidemiological infectious disease perspective, situates individuals as the “host;” tobacco products as the “agent;” the tobacco industry as the “vector;” and the broader context, including policies, as the “environment.” As the vector, the tobacco industry influences individual (or host) tobacco use behaviors through the development and marketing of tobacco products (agent) and by taking actions—including social, community, legal, and political tactics (e.g., counteracting tobacco control policy or programmatic efforts)—that may influence the broader environment (Cruz 2009; Farrelly 2009; Giovino et al. 2009; Garcia-Cazarin et al. 2020).

Disparities are explored in this chapter through the lens of tobacco retailing and the marketing and promotion of tobacco products through new and traditional media. The studies included in this section focus on differences in (a) exposure to tobacco industry influences across population groups and disparities in outcomes between groups and (b) the strength of the association between particular tobacco industry influences and tobacco product use across demographic groups (i.e., interaction effects) (Ward et al. 2019).

## Influences of the Tobacco Retail Environment

This section reviews evidence on the influence of tobacco marketing in the retail environment on tobacco-related health disparities in the United States as it relates to the community environment (i.e., the density or proximity of tobacco retailers) and the consumer or store environment (advertising, promotion, and price).

### Literature Review Methods

A literature search was conducted in PubMed and the Web of Science electronic databases. The literature searches related to the density of tobacco retail outlets focused on studies published between 2008 and 2021 to avoid duplication of the literature reviewed in NCI Tobacco Control Monograph 19. Studies in which data collection occurred before 2000 were excluded. Specific search terms are listed in Table 5A.1 in Appendix 5.1. Other potentially relevant articles were identified from the references listed in the articles that met the inclusion criteria. The search was also supplemented with literature nominated by colleagues and reviewers with relevant expertise.

### Community Environment

An estimated 380,000 retailers sell tobacco in the United States (Center for Public Health Systems Science 2014; Federal Register 2016), resulting in the potential for frequent exposure to commercial tobacco products in the retail environment. Although tobacco retailers in the United States are numerous, their geographic distribution is not uniform, resulting in more ubiquity of commercial tobacco in some places than in others (Lee et al. 2017). Differences in access to and availability of tobacco products may be a social justice issue because such differences may contribute to disparities in tobacco use and tobacco-related disease (Lee et al. 2017).

Figure 5.1 Host-Agent-Vector-Environment model for commercial tobacco use

The HAVE model positions individuals as the “host.” Host factors include knowledge, attitudes, and beliefs; biological factors; and demographic characteristics. Tobacco products are the “agent.” The tobacco industry—including manufacturers, distributors, vendors, and the retail environment—serves as the “vector.” The broader context is composed of the “environment,” such as tobacco control policies and programs, pack warnings, tobacco taxes, limits on product marketing, smokefree rules, informational campaigns, access to cessation services, and product standards. The tobacco industry influences tobacco use behaviors (initiation, brand selection and switching, usage patterns, polyose, nicotine dependence, quitting and relapse) and harmful exposures (carbon monoxide, nicotine, polycyclic aromatic hydrocarbons, volatile organic compounds, metals, and tobacco-specific nitrosamines) that leads to morbidity and mortality outcomes in individuals.

Source: Hyland and colleagues (2017), adapted with permission.

In 2010–2011, almost half of U.S. adolescents (13–16 years of age), who were surveyed using an internet panel, reported that they had visited convenience stores, the most common type of tobacco retailer, weekly (Sanders-Jackson et al. 2015). Frequent exposure to tobacco retailers among youth is a concern because studies show that living in an area with a high density of such retailers may be associated with trying smoking (Pokorny et al. 2003; McCarthy et al. 2009). Greater density of tobacco retailers around schools has also been found to be associated with smoking experimentation among high school students in urban settings but not among high school students or middle school students in rural settings (McCarthy et al. 2009).

Some studies of youth also suggest that those living in neighborhoods with the highest retailer density have a higher prevalence of smoking than youth living in neighborhoods with lower retailer density (Novak et al. 2006; Henriksen et al. 2008). For example, the prevalence of smoking was 3.2 percentage points higher at schools in neighborhoods with the highest tobacco outlet density than it was at schools in neighborhoods without outlets, but presence of an outlet within 1,000 feet of a school and the distance to an outlet from school were not associated with the prevalence of smoking (Henriksen et al. 2008). Additionally, another study found that the more tobacco retailers surrounding a school, the more likely school-aged youth were to purchase their own cigarettes (Leatherdale and Strath 2007). Although another study found no association between retail density and student reports of buying cigarettes from a store, it found a significant linear trend between decreases in retailer density and increases in borrowing cigarettes among students who smoked experimentally (McCarthy et al. 2009). Furthermore, a study of 6th-, 7th-, and 8th-grade students found no association between higher levels of retail tobacco availability and continued smoking, defined as smoking on one or more days in the past 30 days among those who had ever tried smoking (compared with those who had ever tried smoking and did not continue to smoke) (Pokorny et al. 2003).

Studies have also explored these relationships among adults. A study of adults reported an association between retailer density and current smoking and between retailer density and daily smoking (versus smoking some days) among people living in metropolitan locations (Golden et al. 2019). However, another study from Northern California suggests that the effect is limited to neighborhoods with higher socioeconomic status (SES) households (Chuang et al. 2005), potentially because the concentration of convenience stores may not be a sufficient indicator of tobacco availability in lower SES neighborhoods. The residential proximity of tobacco retailers (e.g., living within 500 meters of a tobacco retailer) is associated with reduced smoking cessation (Reitzel et al. 2011; Cantrell et al. 2015a) and with increased risk of relapse (Chaiton et al. 2018). Additionally, in a study of 475 adult residents of Washington, D.C., who were attempting to quit smoking, participants had 1.0 (median) and 2.7 (mean) contacts with a tobacco retailer per day (Kirchner et al. 2013). Contrary to expectations, daily exposure to tobacco retailers was significantly associated with lapsing when cravings to smoke were absent or low, which may indicate that such exposures can influence lapses when other temptations to smoke are relatively low (Kirchner et al. 2013). However, increased risk of relapse or reduced cessation in areas with high retailer density has not been found for all populations.

In addition, Henriksen and colleagues (2004; 2010) found that frequency of visits to tobacco retailers is a risk factor for young people’s experimenting with and initiation of smoking. Surveys of more than 2,125 students in 6th, 7th, and 8th grades found that weekly or more frequent visits to tobacco retailers was associated with 50% higher odds of ever smoking (Henriksen et al. 2004). Later, a longitudinal research study of 1,681 adolescents (11–14 years of age) who had never smoked found that students who visited the types of stores containing the most cigarette advertising (convenience, liquor, and small grocery stores) at moderate frequencies (between twice a month and twice a week) at baseline were 64% more likely to have initiated smoking 12 months later than their peers who reported low visit frequency (less than twice a month) to such stores at baseline (Henriksen et al. 2010). Students who reported high frequency (more than twice a week) of visiting stores containing the most cigarette advertising at baseline were 158% more likely than students who reported low visit frequency to have initiated smoking 12 months later. Greater frequency of store visits, as reported at baseline, remained significantly associated with higher likelihoods of smoking initiation 30 months later (Henriksen et al. 2010).

#### Relationships Between the Density of Tobacco Retailers, Race and Ethnicity, and Income

Several studies have examined the relationship between the density of tobacco retailers and such neighborhood demographic characteristics as racial and ethnic composition and level of income at the state or city level. Studies have consistently found a greater density of these retailers in neighborhoods with higher percentages of Black residents (Schneider et al. 2005; Fakunle et al. 2010, 2019a; Yu et al. 2010; Loomis et al. 2013; Tucker-Seeley et al. 2016; Ribisl et al. 2017b; Mills et al. 2022) and Hispanic residents (Schneider et al. 2005; Fakunle et al. 2010; Siahpush et al. 2010a; Yu et al. 2010; Loomis et al. 2013; Reid et al. 2013; Duncan et al. 2014; Tucker-Seeley et al. 2016; Ribisl et al. 2017b; Mills et al. 2022). Higher densities of tobacco retailers have also been found in lower income neighborhoods (Schneider et al. 2005; Fakunle et al. 2010, 2016, 2019a; Siahpush et al. 2010a; Yu et al. 2010; Mayers et al. 2012; Loomis et al. 2013; Reid et al. 2013; Tucker-Seeley et al. 2016; Galiatsatos et al. 2018; Glasser et al. 2022).

However, findings from studies examining tobacco retailer density as it relates to racial and ethnic neighborhood composition and neighborhood SES have not always been consistent across states and cities or in their approaches to measurement (Siahpush et al. 2010a; Mayers et al. 2012; Duncan et al. 2014; Fakunle et al. 2016). For example, in a random sample of 94 census tracts in Omaha, Nebraska, Siahpush and colleagues (2010a) found, based on a simple regression, that the percentage of stores that sell tobacco was positively associated with the percentage of non-Hispanic Black residents and the percentage of Hispanic residents in neighborhoods. However, when using geographically weighted regression (i.e., allowing for local parameters to be estimated rather than assuming a constant relationship between variables across a study area) in 80 census tracts in Polk County, Iowa, Mayers and colleagues (2012) found no association between the density of tobacco retailers and the percentage of Hispanic residents, and a negative association between the density of tobacco retailers and the percentage of African American residents (i.e., lower outlet density in tracts with higher proportions of African American residents). Duncan and colleagues (2014) also found no significant association in multivariate spatial regression analyses between the density of tobacco retailers and neighborhood demographic characteristics in 167 census tracts in Boston. However, the authors attributed this finding to the potential differential siting of tobacco retailers near large populations of college students given the large number of college and university campuses in Boston, most of which are located outside neighborhoods with more non-White residents than White residents and with more lower income residents than higher income residents.

Schwartz and colleagues (2021) found that, across 3,846 subregions in 13 cities in Ohio, the subregions with a higher prevalence of African American and Hispanic people and people with incomes below the poverty level had higher densities of tobacco retailers. These researchers also found an association between historical redlining and tobacco retailer density. Established by the federal government in the 1920s and 1930s, redlining was a discriminatory housing policy that discouraged banks from offering mortgages in neighborhoods that had a high percentage of residents from certain racial and ethnic groups (U.S. Department of Justice 2021; Legal Information Institute n.d.). Schwartz and colleagues (2021) found that historical redlining grades (e.g., “best,” “still desirable,” “definitely declining,” and “hazardous”) were associated with the modern-day density of tobacco retailers in these Ohio cities. Thus, inconsistencies across state- or city-level studies may be related to the unique demographic composition of particular communities, the different covariates used, and the lack of a standardized measurement for the density of tobacco retailers, which may limit the generalizability of findings.

Five studies examined disparities in the density of tobacco retailers in national samples of such retailers. Using a single sample of tobacco retailers from 2007 and U.S. census tract data, Rodriguez and colleagues (2013, 2014) considered the role of urban and rural geography in two national studies. The density of tobacco retailers was positively associated with the proportion of families experiencing poverty, the proportion of women older than 25 years of age without a high school diploma or equivalent, and the proportion of Hispanic and Black residents in a U.S. census tract and in urban areas compared to non-urban areas (Rodriguez et al. 2013). This study also found that the density of tobacco retailers was negatively, or inversely, associated with average household size (i.e., larger average household size was associated with lower tobacco retailer density); this inverse association between household size and tobacco retailer density was stronger in urban areas than in non-urban areas. Many studies of density use census tracts, which are relatively stable subdivisions of counties that have a population size between 1,200 and 8,000 people (United States Census Bureau n.d.), as a unit of analysis for a neighborhood, and classify each census tract’s density as a function of its population and size. In the study by Rodriguez and colleagues (2013), urbanicity was derived from the rural–urban commuting area classification system, which uses commuter patterns to classify census tracts. Urban census tracts were associated with a 32% increase in the density of tobacco retailers compared with nonurban census tracts (Rodriguez et al. 2013). The relationship between all neighborhood sociodemographic characteristics, except poverty, and the density of tobacco retailers varied by urban and rural geography. For example, the relationship between the density of tobacco retailers and a larger proportion of Hispanic residents was stronger in urban areas than in rural areas (Rodriguez et al. 2013).

In a subsequent study, Rodriguez and colleagues (2014) used mixture regression analysis to determine the optimal number of latent disparity classes among all U.S. census tracts by modeling the relations of the proportion of Black people, Hispanic people, and families living in poverty with tobacco outlet density while controlling for urban or rural status. The authors identified additional heterogeneity in the relationship between the density of tobacco retailers and sociodemographic characteristics in urban and rural census tracts according to level of disparity class, resulting in six latent disparity classes (low, moderate, and high disparity classes in both rural and urban areas). In rural areas, there was a positive relationship between density of tobacco retailers and the composition of Hispanic census tracts in high-disparity class tracts, but a negative relationship was found in rural areas with low- and moderate-disparity classes; an increase in the proportion of Hispanic people in low- and moderate-disparity class census tracts was associated with a decrease in tobacco outlet density. In urban census tracts, there was a positive relationship between tobacco outlet density and composition of Hispanic neighborhoods in both high- and moderate-disparity class tracts, but no statistically significant relationship was observed in low-disparity class tracts. Because the analysis focused on the proportion of non-Hispanic Black populations, there were few differences in tobacco outlet density across levels of disparity classes in rural census tracts. However, for urban areas, each quartile increase in the proportion of Black people was associated with a 5.7%, 2.2%, and 1.4% increase in tobacco outlet density in high-, moderate-, and low-disparity class census tracts, respectively. With respect to poverty level in both rural and urban areas, a strong positive relationship was found between an increasing proportion of families living in poverty and tobacco outlet density for the high- and moderate-disparity class census tracts; the positive relationship between poverty and tobacco outlet density was stronger in urban areas than in rural areas and across all levels of disparity classes (Rodriguez et al. 2014).

Studies using national samples of tobacco retailers must be interpreted with consideration of regional residential patterns of segregation and migration. For example, in 2012–2015, among rural Hispanic residents, 38.5% lived in the West South-Central U.S. census division, compared with only 0.6% in New England (James et al. 2017). Thus, national-level studies examining the intersection of ethnicity and rurality should also account for regional, state, and local differences.

Using a national sample of tobacco retailers in 2012, Lee and colleagues (2017) found in unadjusted models that the density of tobacco retailers was highest in neighborhoods with proportionately more Black residents and lowest in neighborhoods with proportionately more White residents or more Asian and Pacific Islander residents; no such relationship was found with respect to the proportion of Hispanic residents. However, the proportion of both Black and Hispanic residents was negatively associated with the density of tobacco retailers when controlling for income, race and ethnicity, and the proportions of vacant housing and renter-occupied units. Instead, both vacant housing and renter-occupied units, serving as proxy variables for neighborhood stability, were positively correlated with tobacco retailer density, even after controlling for income and race and ethnicity (Lee et al. 2017). However, in another study that used national tobacco retailer data at four timepoints (2000, 2007, 2012, and 2017), Mills and colleagues (2022) found significant, positive relationships between tobacco retailer density and the percentage of Black residents, Hispanic residents, and vacant housing units in a census tract; and lower income was associated with lower retailer density. Between 2000 and 2017, Mills and colleagues (2022) found that the income–retailer density and vacant housing–retailer density relationships weakened.

D’Angelo and colleagues (2016) examined disparities in the proximity of tobacco and fast-food retailers to public schools using a national sample of schools in 2011. Schools comprising the top quartiles of Hispanic students, Black students, and students receiving free or reduced-price lunch had an average of 9.2, 9.6, and 10.9 tobacco outlets near schools, respectively, compared to an average of 2.8 tobacco outlets near schools with the highest quartile of White students. In adjusted models, the number of tobacco retailers near schools was 4% greater for each 10% increase in the proportion of enrollment of Black students and students from lower income families but 8% greater for each 10% increase in the proportion of enrollment of Hispanic students.

Elsewhere, Giovenco and colleagues (2019a) examined the impact of New York City’s tobacco-free pharmacy law, which was implemented in 2018, on the density of tobacco retailers. Density reduction was greatest in neighborhoods with higher median household incomes and a greater proportion of non-Hispanic White residents. Farley and colleagues (2020) examined the impact of the 2009 federal prohibition of flavored cigarettes (excluding menthol) and New York City’s additional prohibition of the sale of other non-menthol flavored tobacco products (excluding e-cigarettes), which was implemented in 2010. Despite local legislation restricting these sales, among 1,557 New York City tobacco retailers in the 2017 New York Retailer Advertising of Tobacco Survey, the availability of any explicit-flavored noncigarette tobacco product (i.e., noncigarette tobacco products that use descriptions or pictures to evoke a specific smell or taste) and the availability of any concept flavor-named noncigarette tobacco product (i.e., tobacco products that use more ambiguous descriptors) were each positively associated with the proportion of Black residents in a neighborhood. Additionally, in multivariate analysis, the availability of explicit-flavored and concept flavor-named large cigars or cigarillos was positively associated with the proportion of Black residents in a neighborhood and the presence of a high school in the neighborhood.

#### Other Neighborhood Sociodemographic Characteristics

Research examining disparities in the density of tobacco retailers for other neighborhood sociodemographic characteristics has been limited. In one such study that used spatial modeling in a 2012 sample of tobacco retailers, Lee and colleagues (2016) found that having higher proportions of female same-sex couples and male same-sex couples in a U.S. census tract was associated with a higher density of tobacco retailers. In models that adjusted for other neighborhood demographic (race and ethnicity and income) and place-based (rurality and the presence of an interstate highway) characteristics, the relationship persisted for male same-sex couples but not for female same-sex couples.

Two studies conducted in California examined the roles of nativity and geography on the density of tobacco retailers in this state. Bostean and colleagues (2022) found that neighborhoods in California with higher concentrations of Latino residents who are foreign-born have higher densities of tobacco retailers but lower densities of alcohol retailers, but there was no statistically significant association between neighborhood composition of foreign-born Asian residents and density of tobacco and alcohol retailers. Henriksen and colleagues (2020) found that, among licensed tobacco retailers in California, there were geographic disparities in product availability and prices in rural versus nonrural counties, with retailers in rural counties being more likely to sell chewing tobacco, to sell larger packs of cigarillos for less than $1, and to charge less for the cheapest pack of cigarettes. For smokeless tobacco products, the price of the leading brand of chewing tobacco, Copenhagen—a brand of Altria, the parent company of Philip Morris USA—was higher in rural stores than in nonrural stores, and the price of Grizzly—a discount brand of chewing tobacco made by American Snuff Company, which is a subsidiary of Reynolds American, Inc., which also owns R.J. Reynolds Tobacco—did not differ between stores in rural and nonrural counties.

Elsewhere, Young-Wolff and colleagues (2014) determined that people with serious mental illness who smoked lived in San Francisco Bay-area neighborhoods with a mean tobacco retailer density that was 2.2 times higher (median 1.13 times higher) than that of the average San Francisco area resident. In univariate analyses, older age, non-White race, neighborhood poverty, and unstable living situations were all associated with living closer to a tobacco retailer among people who smoked and had serious mental illness. For New York City in October 2016, Rogers and Vargas (2018) found that 82% of supportive housing facilities for people with mental illness had at least one tobacco retailer within 500 feet; comparatively, 56% of other residential properties that did not provide supportive housing for people with mental illness had at least one tobacco retailer within 500 feet.

In another study, Hall and colleagues (2019) examined the impact of corporate changes in the sale of tobacco products on the density of three tobacco retailers in 12 southeastern states. Specifically, CVS, a large pharmacy chain, had discontinued the sale of tobacco products in 2014, but two large discount chains offering very low prices, Family Dollar and Dollar General, had started selling tobacco products in 2012 and 2013, respectively. From 2012 to 2014, the decision by CVS decision to stop selling tobacco reduced the density of tobacco retailers in the Southeast by 0.45 stores per 10,000 adults. However, decisions by Family Dollar and Dollar General to sell tobacco led to an overall increase in the density of tobacco retailers by 1.17 stores per 10,000 adults, and increases in density were even larger in rural counties.

#### Density of Vape Shops and Hookah Establishments

Seven studies examined the relationship between the density of vape shops and neighborhood-level demographic characteristics. In the U.S. sample of the 2016 International Tobacco Control Four Country Vaping and Smoking Survey, vape shops were the most common place for adults who use e-cigarettes daily or weekly to purchase their products (43.3% compared with 26.8% who purchased online and with 29.9% who purchased at other tobacco retailers) (Braak et al. 2019). According to data from the 2021 National Youth Tobacco Survey (NYTS), vape or tobacco shops (20.2%) were the second most common sources of tobacco products among middle and high school students who currently used tobacco products, behind social sources (22.5%) (Gentzke et al. 2022). Vape shops differ from conventional tobacco retailers (e.g., convenience stores) because they may sell only tobacco products, including e-cigarettes; they may focus on selling e-cigarettes but not conventional tobacco products; and/or they may be “head shops” or smoke shops (Kong et al. 2017a; Lee et al. 2018). Using a national sample, Dai and colleagues (2017) found that the density of vape shops was higher in urban neighborhoods than in nonurban neighborhoods. In urban areas, the density of vape shops was higher in neighborhoods with greater proportions of young adults, adults 30–44 years of age, and Hispanic or Asian residents. In nonurban areas, the density of vape shops was higher in neighborhoods with greater proportions of African American or Hispanic residents. The density of vape shops in urban areas was also lower in areas with a greater proportion of residents with a college degree, but the density of vape shops did not differ by level of educational attainment in nonurban areas. In a different study, which compared the density of vape shops located near a college campus by urban or rural location, Dai and Hao (2017) found a higher density of vape shops near college campuses that were located in cities compared with college campuses that were located in rural areas. Bostean and colleagues (2018), studying Orange County, California, and Wheeler and colleagues (2020), studying Virginia, found a greater density of vape shops in neighborhoods with a larger proportion of Hispanic residents; in the California study, the density of vape shops was also greater in neighborhoods with a larger proportion of Asian residents. In contrast to these studies, Giovenco and colleagues (2016) used data from New Jersey and found that the odds of a census tract having at least one vape shop were greater in neighborhoods with lower percentages of Hispanic and Black residents and with middle-income tracts (as opposed to higher income). Lee and colleagues (2018), however, noted that discrepancies in findings across studies may be related to the different ways in which vape shops were defined. Giovenco (2018) posited that findings among vape shops that sell only e-cigarettes may diverge from vape shops that sell e-cigarettes and other tobacco products, where vape shop density patterns are more like those seen for cigarettes. Chido-Amajuoyi and colleagues (2020) found that neighborhoods with a higher proportion of non-Hispanic Black residents in Austin, Texas, had lower odds of having vape shops, and neighborhoods with a higher percentage of residents with incomes below the federal poverty level had higher odds of having vape shops. Further, 40% of vape shops were located within a half mile of a middle or high school. Similarly, Wheeler and colleagues (2020) found that neighborhoods in Virginia with higher levels of socioeconomic disadvantage had a greater density of vape shop outlets. Finally, Venugopal and colleagues (2022), examining the incidence of vape shops in U.S. census tracts, found no disparity by race or ethnicity of youth, but the incidence of vape shops in the two lowest SES quintiles was nearly double that of vape shops in the highest SES quintile. Further, authors found increasing incidence of vape shops in neighborhoods with poor air quality, measured as nitrogen dioxide levels in 2018.

Very few studies published during the relevant search timeframe examined the density of hookah establishments by neighborhood demographic characteristics. One study (Kates et al. 2016) examined the proximity of hookah establishments to colleges and universities nationwide and found that public universities were less likely than private institutions to have a hookah establishment within 3 miles. Another study found that the density of hookah establishments in North Carolina and Virginia was greater in areas with more male residents and more Hispanic residents but not more Black residents (King et al. 2020). This study also found a bimodal pattern for the density of hookah establishments by SES, with higher density in areas where more residents held bachelor’s degrees or higher and in areas with more households living below the federal poverty level (King et al. 2020). Additional research is needed to better understand the relationship between the distribution and proximity of hookah establishments and hookah-related health disparities.

### Consumer or Store Environment

The content of tobacco marketing in retail spaces differs across demographic groups when such marketing is defined as advertising, promotions, and price. This section focuses on the availability and placement of tobacco advertising in retail stores, and later sections address targeted advertisements in mass media and other media channels.

#### Influence of Marketing and Advertising on Tobacco-Related Health Disparities

In 2022, the tobacco industry spent $8.05 billion to market cigarettes and $572.7 million to market smokeless tobacco products (Federal Trade Commission 2023a,b). In 2019, major e-cigarette manufacturers spent $1.033 billion on the advertising and promotion of e-cigarettes; this number declined to $719.9 million in 2020 (Federal Trade Commission 2022). Retail marketing includes store advertising, such as company-branded posters on the exteriors of tobacco retailer locations, and price promotions, such as offering coupons for discounts off the price of a pack of cigarettes (NCI 2008). Qualitative research among tobacco retailers in the United States—including 29 retailers in 21 states (Feighery et al. 2003) and 63 owners and managers of small food stores in lower income neighborhoods in 4 cities (D’Angelo et al. 2020a)—suggests that manufacturers of tobacco products often establish contracts directly with the owners of retail stores to have their branded advertisements and promotions placed on store exteriors and interiors and to have their products priced cheaply. In a field study that included direct observations of 2,230 tobacco retailers from 97 counties in the contiguous United States, 95% of stores had at least one marketing material that advertised tobacco products at the point of sale, with an average of 29.5 total tobacco marketing materials per store (Ribisl et al. 2017a). Importantly, the risk of future smoking has been shown to increase with exposure to tobacco marketing (Shadel et al. 2012; USDHHS 2012a). Additionally, based on a 2015 systematic review, studies across different designs, settings, and measures document an association between exposure to tobacco marketing in retail stores and smoking (Robertson et al. 2015). In brief, advertisements attract new consumers and act as cues to people who currently smoke or formerly smoked. In addition, exposure to tobacco marketing is strongly associated with a greater likelihood of tobacco use initiation and progression toward regular use (NCI 2008).

##### Race and Ethnicity, Income, and Education

Disproportionate exposure to tobacco marketing among people from disparate racial and ethnic groups and people living in communities with lower incomes may contribute to higher tobacco use among these groups. Importantly, prior to the 1998 Master Settlement Agreement—which banned cigarette advertising on outdoor billboards—tobacco companies engaged in prominent billboard marketing of cigarettes that reached large numbers of youth and were disproportionately concentrated in neighborhoods with greater proportions of lower income residents and of African American residents (Luke et al. 2000; NCI 2008). Although cigarette billboards are no longer permitted, several studies have reported that tobacco advertising is more prevalent in neighborhoods with greater percentages of residents from minoritized racial and ethnic groups (Luke et al. 2000; Seidenberg et al. 2010; Widome et al. 2013; Hillier et al. 2015; Kirchner et al. 2015), with lower incomes (Barbeau et al. 2005; Seidenberg et al. 2010; Siahpush et al. 2010b; Hillier et al. 2015), or with lower socioeconomic status (Barbeau et al. 2005). However, research examining differences in tobacco marketing by the racial and ethnic composition of neighborhoods has been limited to Black or African American, Asian, and Hispanic or Latino groups, with little examination of disaggregated ethnic groups.

Studies have also investigated the intensity of advertising in specific communities. For example, Seidenberg and colleagues (2010) found that storefront cigarette advertisements were larger in communities with greater proportions of African American residents and residents with lower incomes. Additionally, Widome and colleagues (2013) used data collectors to assess intensity of store advertising in St. Paul, Minnesota, according to four categories: none, discreet, moderate, or “in your face,” which were based on the estimated percentage (0%, <10%, 10–25%, and >25%, respectively) of the property that was covered by tobacco advertising. Authors reported greater likelihood of having “in your face” or “moderate” levels of exterior advertisements in neighborhoods with greater proportions of Asian residents, Black or African American residents, residents receiving public assistance, and residents younger than 18 years of age. Neighborhoods with greater proportions of White residents had lower likelihoods of “in your face” and “moderate” levels of exterior advertising. No such relationships were detected for interior advertising (Widome et al. 2013).

However, studies have not found significant relationships between tobacco advertising and neighborhoods with greater proportions of Hispanic residents (Feighery et al. 2008; Siahpush et al. 2010b; Widome et al. 2013). Feighery and colleagues (2008), who examined changes in the number of tobacco advertisements in retail stores from 2002 to 2005 in California, found that advertising increased more rapidly in neighborhoods with an above-average proportion of African American residents. Finally, Hillier and colleagues (2015) found that in Philadelphia, Pennsylvania, tobacco advertising was more common in retail stores that accepted funds from one or both of two federal food assistance programs: the Supplemental Nutrition Acceptance Program (SNAP) and the Special Supplemental Nutrition Program for Women, Infants, and Children (WIC). Having more tobacco advertising in stores that accept SNAP and WIC may increase tobacco-related marketing disparities for families with lower incomes and those with young children, potentially increasing tobacco-related health disparities.

The tobacco industry has a long history of engaging in targeted marketing. NCI Tobacco Control Monograph 19 concluded that “Targeting various population groups—including men, women, youth and young adults, specific racial and ethnic populations, religious groups, the working class, and gay and lesbian populations—has been strategically important to the tobacco industry” (NCI 2008, p. 11). Studies reviewed for this Surgeon General’s report document tobacco industry targeting of specific racial and ethnic populations of youth. For example, Widome and colleagues (2013) found that tobacco advertisements placed at less than 3 feet from the ground, which is eye level for young children, were more common in neighborhoods with relatively more Black or African American people than people of other races and ethnicities. Mills and colleagues (2018) found menthol advertising was more prevalent in neighborhoods in the third and lowest income quartiles than in neighborhoods in the highest income quartile. Seidenberg and colleagues (2010) found that overall, the proportion of detached advertisements (i.e., advertisements separated from the storefront) and advertisements located within 1,000 feet of schools did not differ significantly in the community of Dorchester in Boston, Massachusetts, which is a predominantly lower income, non-White community, compared with Brookline, a suburb of Boston that is a predominantly White, higher income community. Comparatively, however, Dorchester had a greater proportion of large and medium-sized advertisements, and when the advertisements were weighted by size, advertisements within 1,000 feet of schools were nearly twice as likely to be found in Dorchester as in Brookline.

##### Menthol Cigarettes, Cigars, and Smokeless Tobacco

Studies in various states or cities have examined disparities in tobacco advertising among retailers and the comparative availability of multiple tobacco products, including menthol cigarettes, cigars, and smokeless tobacco. Retail advertising for menthol cigarettes is more common in neighborhoods with greater percentages of African American people, youth, and residents with lower incomes (Seidenberg et al. 2010; Henriksen et al. 2012; Widome et al. 2013; Roberts et al. 2015).

In Ohio, Roberts and colleagues (2015) found that retail marketing for cigars and cigarillos was most common in neighborhoods with higher percentages of African American residents, and advertising for cigarillos was also most common in economically disadvantaged neighborhoods. In addition, the variety of tobacco products advertised outside retail stores (e.g., on windows, doors, sidewalks) was greater in urban, economically disadvantaged African American communities than in urban, economically disadvantaged White communities and rural White communities, regardless of economic position (Roberts et al. 2015). Cantrell and colleagues (2013) found that in Washington, D.C., availability of little cigars and cigarillos was more common in neighborhoods with greater proportions of African American people than in neighborhoods with lower proportions of African American people, and exterior advertising of little cigars and cigarillos was greatest in neighborhoods with higher proportions of youth and of African American people. In New Jersey, Giovenco and colleagues (2018) found greater availability of cigars and cigarillos in retailers near high schools that had a greater percentage of students receiving free or reduced-price lunches and near schools with predominantly non-White students. In New York City, Giovenco and colleagues (2019b) found that the availability of 99-cent cigarillos was higher in neighborhoods with larger proportions of Black and Hispanic residents and with more lower income residents than in neighborhoods with smaller proportions of Black and Hispanic residents and with more higher income residents.

For smokeless tobacco, availability and promotion were lower in retailers near high schools with a greater percentage of students receiving free or reduced-price lunches and near schools with predominantly non-White students (Giovenco et al. 2018). Similarly, in two counties in Minnesota, Widome and colleagues (2012) found a greater number of advertisements for smokeless tobacco in neighborhoods with fewer youth, fewer Black or African American and Asian residents, and fewer people receiving public assistance.

At least some of the findings from these studies likely represent an interaction effect of racially and ethnically segregated communities and poverty on exposure to retail tobacco marketing (Sheehan 2014). For example, communities with high proportions of African American and Hispanic residents are disproportionately of lower SES (Quillian 2012). Thus, studies that examine the relationship between racial and ethnic composition of neighborhoods and retail marketing of tobacco products could consider controlling for neighborhood SES (Sheehan 2014). However, the high collinearity that can exist between neighborhood SES and racial composition does not aways allow for differentiation between effects of SES and racial composition in neighborhoods (Cantrell et al. 2014). For a review summarizing disparities in the retail marketing of tobacco products, see Lee and colleagues (2015c).

##### E-Cigarettes

Disparities in the advertising of e-cigarettes are important because exposure to advertising for e-cigarettes is associated with use of these products among youth (USDHHS 2016), and e-cigarettes are the most commonly used tobacco product among youth across all measured racial and ethnic groups (Gentzke et al. 2022). To date, some studies suggest that e-cigarette advertising and availability were most prominent, at least initially, in neighborhoods with a greater proportion of non-Hispanic, White residents—suggesting that advertising and marketing patterns for e-cigarettes did not mirror the patterns found for most other types of tobacco products when they are introduced to the tobacco marketplace (Rose et al. 2014; Wan et al. 2017; Giovenco et al. 2018, 2019b).

Focusing on the Omaha, Nebraska, metropolitan area, Wan and colleagues (2018) found that after adjusting for covariates, the density of retail advertising for e-cigarettes was greatest in neighborhoods with lower median household incomes. In an earlier study by Wan and colleagues (2017), stores in Omaha were most likely to have advertisements for e-cigarettes if they were located in neighborhoods with relatively greater percentages of non-Hispanic White residents, higher per capita income, and higher percentages of people with at least a high school education.

However, D’Angelo and colleagues (2020b), in a study with later data, found indicators of more widespread distribution of e-cigarette advertising and availability in stores that sell cigarettes. In New York City, Giovenco and colleagues (2018) found that e-cigarettes were more likely to be sold near schools in which most students were White and least likely to be sold near schools in which the majority of students was non-White. Similarly, retailers were least likely to display advertisements for e-cigarettes in neighborhoods with the highest quartiles of Black and Hispanic residents (Giovenco et al. 2019b). In Los Angeles County, Escobedo and colleagues (2020a) found that e-cigarettes, flavored e-cigarettes, and self-service displays of e-cigarettes were less available in communities with a greater proportion of African American, Hispanic or Latino, American Indian, and Korean American residents with lower income levels than in communities with a greater proportion of non-Hispanic White residents with lower income levels. However, no significant differences were found in the availability of price promotions for e-cigarettes. In Baltimore, Fakunle and colleagues (2018) found greater availability of e-cigarettes in alcohol retailers located in neighborhoods (census tracts) in which (a) the percentage of non-White people was higher than the citywide average for this population and (b) the median household incomes were below the citywide median. Elsewhere, in a study involving seven counties in Ohio, Roberts and colleagues (2015) found that external promotions for e-cigarettes were most common in neighborhoods with greater percentages of African American residents. Finally, using national samples of tobacco retailers in 2012, Rose and colleagues (2014) found greater availability of e-cigarettes in neighborhoods with higher median household incomes and lower percentages of African American or Hispanic residents. However, by 2015, a follow-up to this study found that e-cigarette retailers had expanded into neighborhoods with more Black residents and almost 80% of tobacco retailers sold e-cigarettes (D’Angelo et al. 2020b). In addition, this study found that, among new e-cigarette retailers that had not sold these products in 2012, the prevalence of e-cigarette price promotions was highest in neighborhoods with greater proportions of Hispanic residents. Further, stores in neighborhoods with the highest proportions of Black residents had more exterior e-cigarette advertisements. Whether retail patterns of e-cigarette marketing will begin to mirror overall patterns of tobacco retail marketing is an empirical question that requires market surveillance over time.

Another marketing strategy unique to vape shops and hookah establishments is promoting the social appeal of these tobacco products—that is, to encourage tobacco use as a pleasurable way to spend time. In such marketing, information is provided on how to use tobacco or vaping products as a hobby, including (a) advertising the places to go (e.g., vape shops, hookah establishments, cigar bars); (b) adding events or features (such as alcohol) in these establishments to encourage consumers to spend time there; and (c) promoting a variety of social ways to use the products, such as producing vape clouds or sharing a hookah device. For example, an analysis of websites about establishments that offered hookah tobacco smoking suggested that 79% of these establishments served food and 41% served alcohol (Primack et al. 2012), providing a gathering place for young adults. Similarly, content analysis of online reviews on Yelp indicated that vape shops that were reported as “bar type” were relatively more likely to be in business than those that were not reported as “bar type,” suggesting an attractive social option for consumers (Kong et al. 2017b). A content analysis of interviews with vape shop retailers found that they were interested in promoting their stores as recreational spaces that include such social aspects as art galleries, music, or a bar (Tsai et al. 2016). One qualitative study of eight leaders of organizations serving people in the lesbian, gay, bisexual, transgender, and queer or questioning (LGBTQ) community in New York City described how hookah establishments may serve as a medium for socialization for people who identify as LGBTQ and how smoking can bond people who share a sexual orientation (Jannat-Khah et al. 2018). In general, little research was found regarding the availability of social settings for tobacco use for different demographic groups.

##### Individual Sociodemographic Characteristics

Studies on disparities in the retail marketing of tobacco products are typically ecological or describe relationships with groups of people in specified geographic areas (Siahpush et al. 2016). Studies have consistently shown that exposure to tobacco marketing in retail stores is associated with current use of conventional tobacco products and e-cigarettes among youth and increased susceptibility to tobacco use among youth who have never smoked (Agaku and Ayo-Yusuf 2014; Mantey et al. 2016; Singh et al. 2016a). Youth exposure to tobacco marketing is higher in retail stores than through other marketing channels (e.g., Internet, newspaper/magazine, TV/movies) (Dube et al. 2013; Agaku et al. 2014; Singh et al. 2016a; Papaleontiou et al. 2020). According to the 2019 NYTS, 79.4% of youth reported exposure to tobacco marketing at retail stores; the prevalence of self-reported exposure was highest among non-Hispanic White (83.1%) youth, followed by Black, non-Hispanic (76.4%), Hispanic (76.2%), and other race, non-Hispanic (68.0%) youth (Wang et al. 2019).

Few studies have examined the relationship between the community-level retail marketing of tobacco products and individual-level sociodemographic characteristics. Consistent with the ecological literature, in adjusted analyses, Siahpush and colleagues (2016) found statistically significantly greater exposure to retail marketing of cigarettes in the Omaha, Nebraska, metropolitan area among study participants who were non-Hispanic Black, had lower incomes, were male, and were younger in age and who reported more frequent visits to stores. In Florida, Bernat and Choi (2018) found that, compared with adolescents living in metropolitan areas, adolescents living in nonmetropolitan areas of the state were more likely to report seeing tobacco advertisements at convenience stores, gas stations, grocery stores, and big-box stores (e.g., Walmart, Kmart) and were less likely to report seeing tobacco advertisements in pharmacies or drug stores. In an analysis of data from Wave 1 of the 2013–2014 Population Assessment of Tobacco and Health (PATH) Study, which focused on associations between race and ethnicity and exposure to tobacco industry marketing, Carroll and colleagues (2020) found greater exposure to tobacco retail advertisements and/or marketing materials among non-Hispanic Black respondents than among non-Hispanic White respondents; such exposure was even lower among non-Hispanic Asian respondents than among non-Hispanic White respondents for a majority of measures of tobacco marketing exposure. In Ohio, Burgoon and colleagues (2019) found that adolescent boys who identified as non-Hispanic Black or another racial and ethnic group reported greater exposure to tobacco retailers than did adolescent boys who identified as non-Hispanic White. In addition, while self-reported marketing exposure was greater among boys from rural areas than among boys from urban areas, potential exposure to tobacco marketing between home and school was greater among boys living in urban areas than among boys living in rural areas. Liu and colleagues (2019), who examined data from the 2016–2018 NYTS, found that in 2018 middle and high school students under 18 years of age who used e-cigarettes in the past 30 days primarily obtained their products from social sources (72.6%), followed by vape shops or other stores that sold only e-cigarettes (16.5%), gas stations and convenience stores (9.8%), the Internet (5.7%), and other locations (e.g., grocery stores, drug stores, kiosks; <2% each). This pattern of access was similar by sex and by race and ethnicity.

Using a national sample of adolescents from Wave 1 of the PATH Study, Moran and colleagues (2019b) found that among adolescents who had never used tobacco products (n = 9,716), those who were African American and those with lower SES (as indicated by the level of education of a participant’s parent) were relatively more likely to report seeing advertisements for cigarettes and non-large cigars than were non-Hispanic White and higher SES respondents. Among adolescents who had ever used tobacco products, this relationship was significant only for ads for non-large cigars. Compared with Hispanic and non-Hispanic White youth, African American youth were also more likely to use e-cigarettes (based on self-reports) because of appealing advertising. Youth in the lowest education group were most likely to self-report that they used e-cigarettes because people in the media or other public figures use them.

According to a national study by Singh and colleagues (2016b) that relied on self-reports in the NYTS, U.S. middle and high school students in 2015 and 2016 saw advertisements for e-cigarettes most frequently in retail stores; exposure in these stores was higher among non-Hispanic White students than among non-Hispanic Black and Hispanic students and students of other non-Hispanic races or ethnicities.

#### Influence of Tobacco Product Promotions and Price Reductions on Tobacco-Related Health Disparities

One of the most effective ways to prevent and reduce smoking is to increase the price of cigarettes (Levy et al. 2004; Chaloupka et al. 2011). In fact, NCI Tobacco Control Monograph 21, developed in collaboration with the World Health Organization, concluded that “[a] substantial body of research, which has accumulated over many decades and from many countries, shows that significantly increasing the excise tax and price of tobacco products is the single most consistently effective tool for reducing tobacco use” (NCI and WHO 2016, p. 151). The 2000 Surgeon General’s Report, Reducing Tobacco Use, further noted that “raising tobacco excise taxes is widely regarded as one of the most effective tobacco prevention and control strategies” (USDHHS 2000, p. 19). The vast majority of tobacco marketing expenditures are for promotions that reduce the price of cigarettes (Federal Trade Commission 2023a). Similar to the case with advertising, research indicates that promotions of tobacco products and the prices to be paid for them vary by neighborhood sociodemographic characteristics.

Studies in single states or cities have found that price promotions for Newport brand menthol cigarettes are most common in neighborhoods with relatively greater percentages of youth and Black students (Henriksen et al. 2012; Waddell et al. 2016) and Black residents (Kephart et al. 2019). Results are mixed for Hispanic youth, with one study finding more price promotions in neighborhoods with greater percentages of Hispanic youth (Waddell et al. 2016) and another finding no significant association (Henriksen et al. 2012). However, previous studies have found no significant relationship between promotions and neighborhood sociodemographic characteristics for such other brands as Marlboro (Henriksen et al. 2012; Waddell et al. 2016; Kephart et al. 2019) and Doral (Waddell et al. 2016).

A variety of studies have reported that cigarettes are cheaper in neighborhoods with greater percentages of certain racial and ethnic groups (Cantrell et al. 2015b; Henriksen et al. 2017), youth (Toomey et al. 2009; Henriksen et al. 2016, 2017; Epperson et al. 2019), and lower income residents (Seidenberg et al. 2010; Henriksen et al. 2017)—a phenomenon known as price discrimination. For example, Seidenberg and colleagues (2010) reported that the mean advertised price for a pack of cigarettes was $0.39 lower in the lower income, predominantly non-White neighborhood of Dorchester (in Boston) than in Brookline (a suburb of Boston), which is a predominantly higher income, White neighborhood. Furthermore, Henriksen and colleagues (2017) found that Swisher Sweets brand cigarillos cost less in California neighborhoods with a greater percentage of school-aged youth and in neighborhoods with lower median household incomes compared with neighborhoods with a lower percentage of school-aged youth and higher median household incomes, respectively.

Several studies have examined Newport brand menthol cigarettes specifically, the most popular menthol brand in the United States (Henriksen et al. 2012, 2016; Epperson et al. 2019; Miller Lo et al. 2022). In California and the United States overall, prices of Newport menthol cigarettes were lower in neighborhoods with a higher proportion of African American residents and of Asian American and Pacific Islander residents, but this relationship did not reach statistical significance with respect to the proportion of Hispanic residents (Henriksen et al. 2016). Additionally, in California, Newport prices were lower in neighborhoods with a higher proportion of youth (5–17 years of age) (Epperson et al. 2019) and Black students (Henriksen et al. 2012, 2016). In contrast, race and ethnicity, age, and income of residents did not predict variation in bottled water prices in California or the U.S. overall (Henriksen et al. 2016).

Similarly, in Washington, D.C., prices for Newport menthol cigarettes were lower in neighborhoods with relatively more African American people and at retailers near public schools compared with neighborhoods with fewer African American residents and retailers near private schools (Cantrell et al. 2015b). Prices for Newport menthol cigarettes were also higher in neighborhoods with higher median family incomes (Cantrell et al. 2015b). In Massachusetts, prices for Newport menthol cigarettes were lower in neighborhoods with a greater percentage of Black residents (Kephart et al. 2019). In addition, more retailers illegally sold Newport menthol cigarettes at $0.25 or more below Massachusetts’ established minimum price in neighborhoods with a greater percentage of Black and Latino residents (Kephart et al. 2019).

A study by Poston and colleagues (2012) using data collected in 2011 suggested that consumer prices after tax for Newport menthol cigarettes were lower at military exchanges, which are not open to the civilian population. People who smoke were able to pay between 18.1% and 26.7% less by purchasing Newport menthol cigarettes at U.S.-based Army, Air Force, Navy, and Marine Corps exchanges rather than at the nearest Walmart. Similarly, using data collected in 2016, Kong and colleagues (2019) found that packs of cigarettes and smokeless tobacco were cheaper at retail stores located on Air Force bases than they were at nearby off-base retailers. As noted in Air Force Instruction 48-104, the U.S. Department of Defense issued a policy stating, “prices of tobacco products shall match the prevailing local price in the community, including the effect of all applicable taxes” (Secretary of the Air Force 2019, p. 10). However, despite this policy, which supersedes similar previous policies by the Air Force, at least one study conducted in 2019 found that some tobacco products continued to be cheaper at retailers on Air Force bases than they were at nearby off-base retailers (Kong et al. 2022a). Similar price-matching policies have been enacted in other branches of the military, such as the Navy (Department of the Navy 2020) and the Marine Corps (McDonald 2017).

Few national studies have examined disparities in the retail marketing of tobacco products. Using a national sample of tobacco retailers audited in 2012, Ribisl and colleagues (2017a) found that 95% of the retailers displayed tobacco marketing and 75% of the stores displayed at least one price promotion. On average, stores in neighborhoods with a higher percentage of non-Hispanic Black residents displayed more marketing materials than stores in neighborhoods with a lower percentage of non-Hispanic Black residents. Any price promotions were most common in neighborhoods with greater percentages of African American people in general and of youth overall. Earlier, drawing on a 2012 sample of national retailers in public school enrollment zones (the area from which schools draw their student population), Henriksen and colleagues (2016) found that the cheapest packs of cigarettes in retailers were sold in stores in neighborhoods with lower median household incomes. Similarly, using a 2015 national sample, Mills and colleagues (2019) found that the cheapest cigarettes were sold in mass merchandiser stores (compared to convenience stores), stores in neighborhoods with lower median household incomes compared with higher median household incomes and in neighborhoods with greater percentages of school-aged youth.

Two national studies have examined disparities in retail marketing for menthol cigarettes, and one national study has examined disparities in the retail marketing of little cigars and cigarillos. Based on data collected in 2015, Mills and colleagues (2018) found that advertising for menthol cigarettes and promotions for Newport brand menthol cigarettes were most common in neighborhoods with more African American residents compared with neighborhoods with fewer African American residents. In another study, Kong and colleagues (2020) found greater availability and a higher frequency of retail advertising and marketing materials for flavored little cigars and cigarillos in neighborhoods with a higher proportion of Black residents and in neighborhoods with lower income residents.

Using a 2012 sample of national retailers, Lee and colleagues (2015b) found that retail marketing of tobacco products did not differ substantially according to the same-sex couple rate (the number of same-sex couples per 1,000 coupled households in a census tract) in ways that would promote health disparities. Later, relying on a 2015 sample of national tobacco retailers, Rust and colleagues (2019) found that interior tobacco price promotions were more common in retailers that accepted payments from the federal food assistance programs, WIC and SNAP, compared with stores without authorization to accept WIC or SNAP. SNAP-authorized retailers were more likely to display interior tobacco advertisements in stores, with no significant difference in exterior advertising; WIC-authorized stores were less likely to display exterior tobacco advertisements, with no significant difference in interior advertising (Rust et al. 2019). Finally, Osman and colleagues (2019) found that, among adults who smoked, the receipt and redemption of coupons were higher among those who (a) were White than among those who were Black or other race, non-Hispanic than among those who were Hispanic, female than among those who were male, and people from minoritized sexual orientation groups than among those who were heterosexual; (b) had difficulties paying bills than among those with no such difficulties; and (c) had attained middle-level education (defined in the study as having attained a GED certificate up to an associate degree) than among those with a college degree or higher.

Only one study examined the prevalence of price promotions in vape shops and differences by community demographics, suggesting that this is an area that needs further attention. Garcia and colleagues (2017) explored marketing in vape shops and found that, of 77 shops in Southern California, 84% offered discounts for e-cigarette products. The study also found that vape shops in predominantly Hispanic communities were the most likely to have discounts and were more likely to have marketing materials tailored for Hispanic consumers than were shops in other communities.

### Disparities in Violations of Retail Tobacco Regulations

FDA regulates the manufacturing, marketing, and distribution of tobacco products in the United States. Research on disparities in retailer compliance with FDA regulations is limited. Frick and colleagues (2012) found no differences in researcher-observed violations of FDA regulations between higher income and lower income neighborhoods in Columbus, Ohio, but in three counties in North Carolina, Rose and colleagues (2013) found higher odds of nonadherence to provisions in the Family Smoking Prevention and Tobacco Control Act (Tobacco Control Act) (2009a) (e.g., continued sales of “light” labeled cigarettes) in neighborhoods with higher percentages of families living below the poverty level, but lower odds of nonadherence in neighborhoods with greater percentages of Black residents overall. In one national study, Lee and colleagues (2015a) found that in 2014, violations of FDA advertising and labeling regulations—as identified by FDA in formal determinations of and inspections for marketing, advertising, and labeling violations—varied by neighborhood sociodemographic characteristics. For example, in adjusted analyses, single cigarettes (which cannot be sold legally under the Tobacco Control Act [2009]) were most often available for purchase in neighborhoods with greater percentages of Black or Latino residents. In contrast, self-service displays where customers could physically access tobacco products for purchase were less likely to be found in neighborhoods with greater percentages of Black or Latino residents. Although rarely found by 2014, false or mislabeled products (typically vending machines with “light” or “mild” labels) were less likely to be found in stores in neighborhoods with greater percentages of residents under the age of 18.

### Tobacco Retail Summary

Regarding the community environment (e.g., retail density and proximity of retailers), most studies, but not all studies reviewed in this section, have found a greater density of tobacco retailers in neighborhoods with higher percentages of Black or African American residents (Schneider et al. 2005; Fakunle et al. 2010, 2019a; Yu et al. 2010; Mayers et al. 2012; Loomis et al. 2013; Tucker-Seeley et al. 2016; Ribisl et al. 2017b), Hispanic residents (Schneider et al. 2005; Fakunle et al. 2010; Siahpush et al. 2010a; Yu et al. 2010; Reid et al. 2013; Duncan et al. 2014; Tucker-Seeley et al. 2016), and residents with lower income levels (Schneider et al. 2005; Fakunle et al. 2010, 2016, 2019; Siahpush et al. 2010a; Yu et al. 2010; Mayers et al. 2012; Loomis et al. 2013; Reid et al. 2013; Tucker-Seeley et al. 2016; Galiatsatos et al. 2018). Data were less consistent for Hispanic residents than for Black or African American residents. In the studies that used national-level data, the associations between neighborhood sociodemographic characteristics and density of tobacco retailers and vape shops varied by urbanicity, suggesting potential interaction effects. One study found that (a) more than 77% of 18,379 schools across 97 U.S. counties had at least one tobacco outlet within 800 meters (about 0.5 miles) and (b) tobacco outlets were more common near schools with greater proportions of Black, Hispanic, and lower income students and less common near schools with greater proportions of White and higher income students (D’Angelo et al. 2016). Another study found that about 40% of vape shops were located within a 0.5-mile radius of a middle or high school in Austin, Texas (Chido-Amajuoyi et al. 2020). Taken together, these studies suggest the importance of investigating tobacco retailer–school proximity in future disparities research. However, there is a gap in the literature focusing on other disparities in addition to race and ethnicity and income. More research is also needed to investigate potential disparities in the density of tobacco retailers among other populations, such as American Indian and Alaska Native people, Pacific Islander people, people of different ethnicities subsumed under aggregated population groups, and people who identify as LGBTQI+. Furthermore, additional research is needed to examine whether disparities in tobacco retailer density, including density of vape shops and other e-cigarette retailers, have changed over time and across space (i.e., across various neighborhoods).

Regarding the consumer and store environment (e.g., advertising, promotions, and pricing), evidence suggests that the tobacco industry strategically uses targeted marketing and advertising of tobacco products in neighborhoods with certain characteristics. Similar to the findings related to disparities in tobacco retailer density, some studies have found that tobacco advertising is more prevalent in neighborhoods with greater percentages of African American residents or residents with lower incomes compared with neighborhoods with lower percentages of African American residents or residents with higher incomes (Barbeau et al. 2005; Seidenberg et al. 2010; Siahpush et al. 2010b; Widome et al. 2013; Hillier et al. 2015; Kirchner et al. 2015). Some brands and varieties of cigarettes are also cheaper in neighborhoods with greater percentages of minoritized racial and ethnic groups, youth, or lower income residents (Toomey et al. 2009; Seidenberg et al. 2010; Henriksen et al. 2012, 2016, 2017; Cantrell et al. 2015b; Epperson et al. 2019; Kephart et al. 2019), which could encourage experimentation and regular use of tobacco products among community members. Additionally, the prices of cigarettes may be lower in neighborhoods with higher proportions of youth, which could increase smoking initiation among youth in these neighborhoods (Toomey et al. 2009; Henriksen et al. 2016, 2017; Epperson et al. 2019). Retail advertising for menthol cigarettes, the only remaining characterizing flavor in cigarettes other than tobacco flavor, is more common in neighborhoods with greater percentages of African American people, youth, and lower income residents (Seidenberg et al. 2010; Henriksen et al. 2012; Widome et al. 2013; Roberts et al. 2015; Mills et al. 2018). Menthol cigarettes also tend to be cheaper in these neighborhoods (Henriksen et al. 2012, 2016; Mills et al. 2018; Kephart et al. 2019). Because menthol cigarettes are associated with increased tobacco initiation and more difficulty quitting, especially among African American people who smoke menthol cigarettes (see Chapter 3) (FDA n.d.), the disproportionate distribution of menthol product-related advertising can further contribute to persistent racial and ethnic disparities in the use of such products.

More studies are needed to examine relationships between the availability of noncigarette tobacco products (e.g., cigars, e-cigarettes, nicotine oral pouches), advertising for these products, and the demographic characteristics of neighborhoods. Studies suggest both greater availability and higher levels of advertising for cigars in neighborhoods with greater percentages of African American and lower income residents (Cantrell et al. 2013; Roberts et al. 2015; Giovenco et al. 2019b; Kong et al. 2020). Among youth, there are also racial and ethnic differences in exposure to advertising for certain tobacco products, such as cigars and cigarettes. On the other hand, advertising patterns for e-cigarettes and smokeless tobacco products appear to differ from patterns for other tobacco products. Specifically, studies suggest that the advertising of e-cigarettes and smokeless tobacco products is relatively more prominent in neighborhoods with higher proportions of non-Hispanic White residents (Widome et al. 2012; Giovenco et al. 2019b). However, in the years since e-cigarettes have been on the market, the targeted advertising of these products may have begun to shift into neighborhoods with greater proportions of members of minoritized racial and ethnic groups (Grilo et al. 2021). Future research should monitor these trends in advertising at the neighborhood level and how they might impact tobacco product use disparities.

## Marketing and Media

The tobacco industry uses an array of communication and promotional tools to market its products to consumers, including social and digital media, traditional or mass media advertising, sponsorships (for noncigarette products), and price promotions. Prior Surgeon General’s reports and NCI Tobacco Control Monograph 19 have already causally linked tobacco marketing to tobacco use (NCI 2008; USDHHS 2012a, 2014), but several developments in the interim have necessitated new examinations of this linkage, including the expansion of tobacco marketing through social media and digital marketing, the expanded landscape of tobacco products, the adoption of different restrictions pertaining to allowable marketing strategies for noncigarette tobacco products compared with cigarettes, and the potential for different levels of exposure to and impact of marketing on tobacco use across populations. This section examines several domains of tobacco control research on channels for tobacco marketing and the relationship between tobacco marketing communications and tobacco use and related disparities. Finally, this chapter includes examples of tobacco product advertising to specific groups in a variety of media (Figure 5.2). Chapter 1 includes a brief history of targeted menthol cigarette marketing, and Chapter 8 includes additional details about current activities of the commercial tobacco industry.

### Literature Review Methods

For this section of the chapter, PubMed, Google Scholar, Ovid, and PsycInfo were searched for articles published between 2008 and December 31, 2021. Specific keyword terms and the search strategy are presented in Appendix 5.1. The articles were reviewed, organized chronologically and thematically, and then the findings were synthesized. Information from research articles was triangulated with data from outside sources exemplifying marketing practices (e.g., websites of nongovernmental organizations, published reports of industry practices and social media use, and news articles).

Figure 5.2 Examples of promotional content for tobacco products aimed at specific population groups through various marketing channels

A LGBTQI+ populations

Source: Ad for ITG Brands’ blu brand e-cigarettes that appeared in, for example, Playboy and US Weekly magazines in 2016 (Trinkets & Trash 2016c).

Source: Instagram post in 2021 by Optimo Cigars, a subsidiary of Swisher International (Trinkets & Trash 2021c).

B Black or African American populations

Source: Instagram post by Puff Bar in 2020 (Stanford Research into the Impact of Tobacco Advertising 2020).

Source: Ad for Altria’s Black & Mild brand cigars that appeared in, for example, Entertainment Weekly, Men’s Journal, Popular Mechanics, and Rolling Stone magazines in 2019 (Trinkets & Trash 2019c).

Source: Instagram post by Swisher Sweets brand cigars in 2018 (Stanford Research into the Impact of Tobacco Advertising 2018).

Source: Website image from Kool brand cigarettes in 2022 (Stanford Research into the Impact of Tobacco Advertising 2022).

C Hispanic or Latino populations

Source: Email that promotes rewards points that consumers can earn from purchasing the Smooth Ice product from Marlboro brand cigarettes and ATLx, a Marlboro Black feature on Latinx artists (Trinkets & Trash 2019d).

Source: Ad for Camel Crush brand cigarettes from 2013 that targeted Spanish-language consumers: “Los dos—tu cigarillo a tu manera” (“Both—your cigarette, your way”) (Trinkets & Trash 2013a).

Source: Email from Marlboro in October 2022 that promotes its rewards program by celebrating Hispanic heritage (Trinkets & Trash 2022d).

D Asian and Pacific Islander populations

Source: Ad for ITG Brands’ Kool brand cigarettes in 2005 (Stanford Research into the Impact of Tobacco Advertising n.d.a).

E American Indian and Alaska Native populations

Source: Branding logo for nicotine-free IndianHead real Indian tobacco e-liquid; (Stanford Research into the Impact of Tobacco Advertising 2021).

Source: Facebook advertisement from Kiyou Smoke Shop (n.d.) that promotes Signal brand tobacco products.

Source: Promotional signage for Seneca Country tobacco products (Countertobacco.org n.d.).

Source: Promotional web advertisement to attract online membership in Signal brand tobacco products (Signal n.d.).

F Lower socioeconomic populations

Source: Email from February 2019 promoting The Lounge section of Newport brand’s website, specifically a $20 friends-night-out challenge (Trinkets & Trash 2019a).

Source: Email from December 2018 holiday season promoting The Lounge, an online feature from Newport brand cigarettes in which consumers can get recipes and read about other stories (Trinkets & Trash 2018b).

Source: Ad for blu brand e-cigarettes that included a parody of a warning label: “Important: Less harmful to your wallet.” The ad ran in, for example, ESPN Magazine and Rolling Stone in 2017 as part of blu brand’s Something Better series (Trinkets & Trash 2018a).

G Rural populations

Source: Ad from 2006 that promotes Longhorn brand smokeless tobacco and doubles as a calendar for the month of April (Stanford Research into the Impact of Tobacco Advertising 2006).

Source: Email from November 2015 that highlights Marlboro brand’s Rockin’ Boots contest for mobile phone users (Trinkets & Trash 2015).

Source: Email from 2022 about the continuation of reward points for consumers of Marlboro brand cigarettes (Trinkets & Trash 2022e).

Source: Ad from 2003 that contains a quotation from a rodeo star indicating that using Copenhagen brand smokeless tobacco is one of his three priorities in life (Stanford Research into the Impact of Tobacco Advertising 2003).

Source: Social media post from 2019 that promotes Swedish Match’s ZYN brand nicotine pouches and an upcoming country music festival (Stanford Research into the Impact of Tobacco Advertising 2019).

Source: Direct mail from September 2018 about weekly mobile coupons for Red Seal brand smokeless tobacco, which is made by U.S. Smokeless Tobacco Company, a subsidiary of Altria. Text on the mailing celebrates American farmers: “We’re proud to call the heartland home” (Trinkets & Trash 2018c).

H Youth and young adult populations

Source: September 2019 cover of Cigar Aficionado magazine that shows a photo of celebrity actor and musician Nick Jonas. The issue also includes a feature story about Nick Jonas (Savona 2019; Storey 2019).

Source: Promotional signage at a vape shop in Lincoln, Nebraska, in 2022 announcing a double discount for students who bring friends to the store (Countertobacco.org 2022a).

Source: Online advertisement from 2016 for college night at the Starbuzz Hookah Lounge in Riverside, California (Stanford Research into the Impact of Tobacco Advertising 2016b).

I Military and veterans and other occupational groups

Source: Ad for Copenhagen brand smokeless tobacco from 2008 that shows two firefighters in action (Stanford Research into the Impact of Tobacco Advertising 2008).

Source: Ad—which appeared in, for example, Car and Driver, Men’s Journal, and Popular Mechanics magazines in 2021—that announces Copenhagen brand smokeless tobacco’s pledge to make donations to charity organizations that support veterans (Trinkets & Trash 2021a).

Source: Screenshot from 2021 about VUSE brand e-cigarette’s initiative to donate $100,000 to disabled American veterans (Trinkets & Trash 2021b).

J Behavioral health

Source: Pole signage outside a cigar retail store in Sarasota, Florida, in 2022 asking consumers to make a decision about spending $200 on therapy or $20 on “a good cigar” (Countertobacco.org 2022b).

Source: Online promotional content about Breakers brand nicotine pouches. The content suggests that by using Breakers, consumers can enhance their focus, boost their energy, and feel relaxed (Lucy n.d.).

### Influences of Tobacco Marketing on Tobacco-Related Health Disparities

The purpose of advertising is to increase the value of a brand. Previous reports have established a causal link between exposure to tobacco marketing and use of tobacco products (NCI 2008; Lovato et al. 2011; USDHHS 2012a, 2014). The 2012 Surgeon General’s report concluded “that there is a causal relationship between advertising and promotional efforts of the tobacco companies and the initiation and progression of tobacco use among young people” (USDHHS 2012, p. 10). Advertising and health communication theories, as well as decades of tobacco control research, provide a strong rationale to expect that exposure to tobacco-related messages on social media will similarly influence tobacco-related attitudes, beliefs, and behaviors.

Theories of advertising are grounded in the premise that promotional messages will generate cognitive and affective responses in people before they buy a product (Lavidge and Steiner 1961; Fishbein and Ajzen 1975; Batra and Ray 1986; MacKenzie et al. 1986; Muehling 1987; Kempf and Smith 1998; Vakratsas and Ambler 1999). The premise underlying health communication theories is that changes in health behaviors can be achieved by providing people with information that shapes their beliefs and attitudes about those behaviors (Fishbein and Ajzen 1975; Ajzen and Fishbein 1980; Bandura 1986; Noar 2005). Characteristics of the message, the source of the message, the person exposed to the message, and the environment in which the exposure occurs can all affect its salience, the cognitive and affective response, and the subsequent behavior (Emery et al. 2012; Albarracin et al. 2014; Tannenbaum et al. 2015; Pierce et al. 2017). Protobacco advertising and promotion is associated with more positive tobacco-related attitudes and beliefs and higher rates of tobacco use, and antitobacco advertising and advertising bans are associated with denormalization of tobacco use and reductions in that behavior (Hamilton 1972; Warner 1977; Hu et al. 1995; Kozlowski et al. 2000; Saffer and Chaloupka 2000; NCI and WHO 2016).

Targeted marketing contributes to tobacco use disparities among disparate populations (Yerger and Malone 2002; Gardiner 2004; Sutton and Robinson 2004; Yerger et al. 2007; USDHHS 2012b, 2014). Targeted promotion may make messages more effective by enhancing their cultural appropriateness, relevance, and reach. For example, menthol cigarette brands have targeted African American people by featuring hip-hop culture, music, and movies in their marketing materials (Hafez and Ling 2006). Liking hip-hop music and self-identifying as a peer among the hip-hop generation have been associated with risk of tobacco use among youth (Mulder et al. 2009, 2010; Lisha et al. 2016; Harakeh and Bogt 2018; Walker et al. 2018). Hip-hop has cultural roots in both Black or African American and Hispanic or Latino communities (Chang 2005). Although the full extent of the tobacco industry’s sponsorship of hip-hop music and support of its subculture is not completely clear, the tobacco industry is known to sponsor a variety of cultural events using a hiphop theme, such as the Kool Mixx promotional campaign launched by Brown & Williamson in 2004 (Pickett 1998; U.S. Marketing & Promotions 1998; Hafez and Ling 2006).

By race, among adults who currently smoke, menthol cigarette use is more prevalent among African American people than among people in other groups (Villanti et al. 2016). Additionally, among adults who smoke, Newport is the most popular brand of menthol cigarettes, and more than half of people who smoke Newport menthol cigarettes are African American (Cohn et al. 2019). In a study of a California city, African American adolescents were found to be more likely than youth from other racial and ethnic groups to recognize Newport, and recognition of the Newport brand has been associated with increased smoking initiation (Dauphinee et al. 2013). The 1998 Master Settlement Agreement restricts the use of such targeted promotions for cigarettes but not for other products in some media channels for marketing, including brand name sponsorship of events such as music concerts. Brand-sponsored events continue to be used to promote other tobacco products, including cigars (Ganz et al. 2018).

In this vein, the marketing of noncigarette tobacco products—such as cigars, cigarillos, and/or smokeless tobacco—is designed to appeal to specific groups, including youth (Kostygina et al. 2016a), people who identify as LGBTQ+, and Hispanic and African American people (Hendlin et al. 2023). Notably, the strategies used to promote these products parallel those used in the past to promote conventional cigarettes.

According to communication inequality theory, population-level disparities in health outcomes may be caused, in part, by inequalities in communication, which result, for example, from such technologies as the Internet being used relatively more often by people with higher incomes and higher levels of educational attainment, by youth and young adults, and by people who are employed than by their respective counterparts (Viswanath and Kreuter 2007; Pew Research Center 2021a). Although this technology gap has declined, with 93% of U.S. adults reporting Internet use in 2021, disparities persist based on age, income, and education. For example, almost all (>99%) young adults, college graduates, and people with incomes over $75,000 use the Internet; however, this figure drops to 75% for people 65 years of age and older and to 86% for people with high school or less education or those with incomes of less than $30,000 (Pew Research Center 2021a). “Communication inequality is defined as the differences among social groups in their ability to generate, disseminate, and use information at the macro level and to access, process, and act on information at the individual level” (Viswanath 2006, p. 222). People living in resource-poor areas, geographically remote areas, or areas with little or no Internet access could be underexposed to positive health messages, such as digital tobacco countermarketing campaigns, and overexposed to negative health messages, such as tobacco marketing, in nondigital media channels. Negative health messages may have a direct effect on health behavior by encouraging tobacco product use, and they may also overwhelm any positive health messages. Messages from tobacco prevention and control programs must compete with a myriad of tobacco marketing materials that a person encounters over the life course.

Disparities in the quantity and quality of health communication experienced by people in certain socioeconomic and racial and ethnic groups may be partially responsible for some tobacco-related health disparities seen in these groups. Research has documented inequalities in health communication and illustrated the contributions of these inequalities to health disparities. For example, Ishikawa and colleagues (2016) conducted a path analysis of data from the nationally representative Annenberg National Health Communication Survey to assess the direct and indirect effects of the relationship between SES indicators (measured by education attainment and household income) and an index of four health behaviors, including tobacco smoking. Results showed evidence of mediation via indirect effects by inequalities in use of health media (e.g., frequency of viewing or reading health sections on TV, in print, and on the Internet) and disparities in social participation (that do and do not lead to differential media use), suggesting that socioeconomic disparities in the use of health media partially explain disparities in health behaviors (Ishikawa et al. 2016).

In the context of tobacco marketing, several well-documented disparities in exposure are consistent with the broader literature on inequalities in communication. For example, an analysis of PATH Study data by Moran and colleagues (2019b) found that among youth who never used tobacco, African American youth and youth of lower SES (defined as youth whose parents have less than a college degree) were more likely to recall having seen ads for cigarettes and non-large cigars and to report being exposed to tobacco-related coupons than their non-Hispanic White and Hispanic counterparts and youth whose parents had a college degree or higher, which was used in the study as a proxy for higher SES. In addition, African American youth were more likely than non-Hispanic White and Hispanic youth to indicate that they “used [e-cigarettes] because the advertising appeals to me” (Moran et al. 2019b, p. 286). Students of lower SES were more likely than students of higher SES to report using e-cigarettes and non-large cigars “because people in the media or other public figures use them” (Moran et al. 2019b, p. 286). A national study found, in unadjusted analyses, that non-Hispanic Black adults were more likely than non-Hispanic White adults and non-Hispanic adults of other races (American Indian, Alaska Native, and multiple races) to trust information about the health effects of using tobacco from tobacco companies; however, this finding was no longer statistically significant in adjusted analyses (Nguyen et al. 2017). Soneji and colleagues (2014) examined a national sample of youth and young adults (15–23 years of age) and found that nonsmoking Hispanic and non-Hispanic Black respondents were more likely to report exposure to tobacco company websites than were non-Hispanic White respondents and that exposure to such marketing was associated with smoking during the past 30 days and with established smoking. However, the study did not find an interaction between marketing exposure and tobacco use by race and ethnicity. Among young adults, Lienemann and colleagues (2019) also found that the relationship between liking a tobacco advertisement and using cigarettes and cigars was stronger among those with lower levels of educational attainment than among those with higher levels of educational attainment, and the relationship between liking ads and using e-cigarettes and smokeless tobacco was stronger among those living below the federal poverty limit compared with those living above poverty. Tan and colleagues (2021) further found that bisexual young adult women had greater aided recall of e-cigarette, cigarette, and cigar ads compared with heterosexual or lesbian/gay young adult women. Ad recall was even greater for bisexual Hispanic women. Heterosexual and bisexual Black women and heterosexual Black men also had higher aided recall of certain types of tobacco product ads compared with their White heterosexual counterparts. Such analyses are becoming more common and have the benefit of teasing apart the differential effects of exposure to tobacco marketing by disparity categories and the potential differential impact of exposure to marketing on tobacco use outcomes.

### Marketing Tobacco Products on Social and Digital Media

The media environment is rapidly changing. Using social and digital online media to market their products has become a prominent marketing strategy for tobacco companies. Such marketing is not subject to the same restrictions that curbed marketing on traditional media, such as (a) the so-called “Broadcast Ban,” which was enacted in the Public Health Cigarette Smoking Act of 1969 (1970) and banned cigarette advertising on television and radio; and (b) the Comprehensive Smokeless Tobacco Health Education Act of 1986 (1986), which banned advertising for cigarettes and smokeless tobacco on “any medium of electronic communication subject to the jurisdiction of the Federal Communications Commission” (Ernster 1989; Centers for Disease Control and Prevention [CDC] n.d.a).

In addition, the Master Settlement Agreement banned cigarette advertising on billboards and also restricted other cigarette marketing, such as using brand names to sponsor events (Public Health Law Center n.d.b). However, the Federal Communications Commission has not sought to regulate the Internet (Campaign for Tobacco-Free Kids 2021). Additionally, advertising for tobacco products on social and digital media is subject to the same mandatory health warnings as it is in other media channels, but such advertising has not been subjected to the Broadcast Ban that prohibits cigarette and smokeless tobacco advertisements on radio and television (Campaign for Tobacco-Free Kids 2021).

Digital and social media marketing strategies may have an additional impact because they are interactive in ways that traditional media are not. The following sections review the literature on trends in social and digital online media marketing overall and potential differences in marketing that may influence tobacco-related health disparities. This section extends the discussion of social media and digital media strategies beyond what was in the 2016 Surgeon General’s report on e-cigarette use among youth and young adults (USDHHS 2016).

Although the prevalence of smoking and sales of cigarettes in the United States have declined since the 1998 Surgeon General’s Report focused on disparities, decreases in the sale of cigarettes have been partially offset by increases in the sale of other tobacco products, including e-cigarettes and cigarillos (Ali et al. 2020, 2022; Wang et al. 2022). In addition, there are now substantial disparities in the use of other types of tobacco products by race, ethnicity, sex, sexual orientation, and gender identity (Emory et al. 2019; Gentzke et al. 2022). In fact, the prevalence of e-cigarette use among youth and young adults exceeds use of combustible cigarettes (see Chapter 2). Youth are exposed to e-cigarette advertising across diverse channels, including social and digital media, and this exposure is associated with lower harm perceptions of e-cigarettes, greater intention to use e-cigarettes, and experimentation with e-cigarettes (Collins et al. 2019).

#### Social Media Marketing

Extensive literature supports the idea that a person’s social interactions and media environment exert significant influences on their tobacco use behaviors (see Chapter 4) (NCI 2008; USDHHS 2012b). However, the ways in which a person interacts socially and the media landscape itself have changed during the past decade. Indeed, digital and social media have become part of everyday life, especially for teenagers: 95% of teenagers reported using at least one social media platform in 2022, most commonly YouTube (95%) followed by TikTok (67%) (Vogels et al. 2022). By 2016, 98%, or almost all, young adults reported regular use of at least one social media site (Villanti et al. 2017). African American and Hispanic adults also use certain social media platforms—such as YouTube, Facebook, Instagram, TikTok, and WhatsApp—at rates higher than such use by White adults (Auxier and Anderson 2021). The nearly ubiquitous use of social media among adolescents (Anderson and Jiang 2018; Vogels et al. 2022) plays a significant role in their daily lives, development, and identity formation (Hur and Gupta 2013; Michikyan and Suárez-Orozco 2016). However, as described in the 2023 Surgeon General’s Advisory, Social Media and Youth Mental Health, inappropriate or harmful content is widely available to youth on social media, and youth who spend more time on social media increase their risk of experiencing poor mental health, including symptoms of depression and anxiety (USDHHS 2023).

In this new media environment, people are targeted by customized information algorithms, and they also curate their own media content. The combined effect of targeted promotions and curated content can create “echo chambers” in which youth and adults consume only the information that supports their worldviews (Slater 2007; Bessi et al. 2015). In this scenario, antitobacco public health media campaigns compete with promotional product marketing campaigns in the social media environment, potentially resulting in confusion and misinformation for the audience.

Additionally, use of social media by youth may differ by sociodemographic factors. Although social media use is fairly ubiquitous across racial and ethnic groups, some differences have emerged in the prevalence of use and in the frequency with which diverse groups access the Internet, which may contribute to disparities in access to digital content. For example, in 2022, Black (56%) and Hispanic (55%) teens were more likely than White (37%) teens to say they are online “almost constantly” (Vogels et al. 2022). Additionally, although access to smartphones is universally high, only 79% of teens who live in households making less than $30,000 say that they have access to a desktop or laptop computer compared with 94% of teens who live in households with income levels of $75,000 or more (Vogels et al. 2022).

Social media use differs substantially by SES. For example, social media use increases with years of education; in 2021, 77% of college graduates used social media but only 64% of people with a high school education or less used it (Pew Research Center 2021b). Additionally, promotional content and marketing are tailored to different populations, an approach known as narrowcasting (Cappella et al. 2015). Although trailing urban and suburban populations, populations in rural areas are increasingly online and on social media, increasing from about 40% in 2010 to 66% in 2021 (Pew Research Center 2021b). Digital and social media channels allow advertisers to quickly access hard-to-reach communities and share targeted messages and promotions with them, creating an environment in which information often extends beyond the reach of traditional media sources.

The tobacco industry has adapted its marketing to the shifting media landscape and is leveraging the new media environment to promote newer tobacco products (CDC 2016; O’Brien et al. 2020; American Lung Association n.d.) while also making combustible tobacco products more appealing, such as by using social media influencers from the United States and other countries to glamorize smoking (Kaplan 2018). Because of limited regulatory oversight, tobacco manufacturers and vendors are able to promote their products through increasingly diverse media channels, including social media (Freeman 2012; Liang et al. 2015). Social media provides an important platform to market tobacco products and engage consumers. Tobacco brands and retail outlets use social media to advertise a broad range of products and devices; update marketing strategies used in previous decades (USDHHS 2016); and recruit celebrities, musicians, and models to endorse their products (Kostygina et al. 2016b; USDHHS 2016).

Early research suggests that content on social media about e-cigarettes, menthol cigarettes, little cigars, and cigarillos is highly prevalent (Huang et al. 2014, 2016; Kostygina et al. 2016b; Rose et al. 2017). For example, estimates of the number of views of e-cigarette-related videos on YouTube exceeded 100 million by June 2013 (Huang et al. 2016). The types of e-cigarette-related social media messages have since grown (Huang et al. 2019; Xie et al. 2021; Sun et al. 2023). In addition to widespread promotion of e-cigarette-related content on YouTube (Huang et al. 2016, 2019; Xie et al. 2021), Twitter (Huang et al. 2014, 2019), Instagram (Czaplicki et al. 2019; Huang et al. 2019; Chu et al. 2021), and TikTok (Tan and Weinreich 2021; Marynak et al. 2022; Sun et al. 2023), Barker and Rohde (2019) found that e-cigarette-related content on Reddit consists primarily of messages about methods of buying and selling e-cigarette products.

From 2014 to 2015, the number of tweets about little cigars and cigarillos exceeded that of e-cigarettes. Using keyword filters, Kostygina and colleagues (2016b) captured over 4.3 million tweets related to little cigars and cigarillos, of which approximately 83% contained references to cannabis (e.g., for blunt use). This is more than twice as many tweets related to little cigars and cigarillos over a 3-month period than the number of posts about e-cigarettes captured over a 5-year time frame (1.7 million, 2008–2013) found by Kim and colleagues (2015).

Additionally, Kim and colleagues (2021) reported that the total amount of tweets about JUUL increased 67 times, from nearly 19,000 in the first quarter of 2017 to more than 1.2 million in the last quarter of 2018. During this period, JUUL became the most popular brand of e-cigarettes in the United States (Kim et al. 2021). In a different study, the most common type (20%) of Twitter post abouts JUUL used person tagging (@username), suggesting that Twitter users were sharing information about specific products (Allem et al. 2018). Similarly, posts related to the use of hookah are prominent on social media and largely reflect positive (60%) sentiment (Allem et al. 2017b).

A modest but growing body of literature suggests that teenagers frequently observe tobacco-related messages on social media. By 2015, 40% of youth (13–17 years of age) and 57% of young adults (18–21 years of age) in the United States indicated they saw e-cigarette advertising online always, most, or some of the time (Truth Initiative 2015). In a study of college students in Hawai‘i conducted between November 2016 and January 2017, exposure on social media to content about e-cigarettes was associated with current e-cigarette use (Pokhrel et al. 2018). Additionally, a study of middle and high school students in rural Tennessee found that e-cigarette use was associated with exposure to tobacco marketing on social media and overall high exposure to tobacco marketing (Peiper et al. 2020). Another study showed that greater social media use and heavier exposure to advertisements of e-cigarette content in social media posts were associated with a greater risk for e-cigarette use among adolescents 13–18 years of age (Vogel et al. 2021).

Coreas and colleagues (2021) found that, among adolescents 12–17 years of age in the PATH Study, those who reported having seen tobacco product-related content posted on social media at any wave of the study (2013–2018) were more likely to experimentally smoke by Wave 4 (2018) compared with those who did not report having seen any tobacco product-related content posted on social media. Furthermore, Shan and Azagba (2022) found that, among adolescents in the PATH Study, the odds of cigarette and e-cigarette initiation among those who follow or like tobacco brands on social media was more than two times the odds of initiation for those who do not follow or like tobacco brands on social media. No studies were identified that examined whether the relationship between social media marketing exposures and tobacco use outcomes varied by race and ethnicity.

Research indicates that populations experiencing tobacco-related health disparities continue to be disproportionately targeted by marketing from the tobacco industry (Primack et al. 2007; Dilley et al. 2008; Cantrell et al. 2013; Brown-Johnson et al. 2014; Lee et al. 2015c; Cruz et al. 2019b; Lempert and Glantz 2019). Since some disparate groups may also use specific social media platforms at relatively higher rates than their counterparts (Auxier and Anderson 2021), the effects of targeted marketing through social media may be even more potent. For example, Emery and colleagues (2014) analyzed data from a nationally representative, cross-sectional online survey of U.S. adults to assess the media diet of lesbian, gay, and bisexual (LGB) and non-LGB people. The analysis showed that LGB people had higher odds of sharing content related to e-cigarettes through social media than non-LGB people (p <0.05). In another study, LGBT adults were exposed more often to tobacco-related media than were non-LGBT adults, and the effect was strongest among people who smoke and are LGBT (Emory et al. 2019). Similarly, African American adults may be more likely than non-Hispanic White people to observe links to social media sites that offer content about tobacco products (e.g., product characteristics and branding information) (Escobedo et al. 2020b). Additionally, in a study of adolescents from Connecticut who were followed from 2013 to 2014, exposure to e-cigarette marketing through Facebook—but not other social media platforms (Twitter, YouTube, Pinterest, or GooglePlus)—was associated with subsequent e-cigarette use after adjusting for age, race, gender, and cigarette smoking status at baseline (Camenga et al. 2018).

In summary, the limited evidence on relationships between social media use, exposure to tobacco-related content on social media, and tobacco product use by demographic characteristics is only beginning to be investigated. Although use of social media and exposure to tobacco marketing through such online media may differ between disparate groups, more work is needed to identify whether such exposures contribute differently to disparities in various tobacco use outcomes by race and ethnicity, sexual orientation and gender identity, or other sociodemographic factors. Additionally, more studies should examine intersectional identities (e.g., race and ethnicity and SES) using interaction terms or stratified models to examine how targeted tobacco marketing may influence tobacco-related disparities among populations with multiple marginalized identities.

#### Influencer Marketing and Sponsored Marketing

The changing media environment has resulted in seismic shifts in advertising strategies. The proliferation of ad blockers on computers and mobile devices has reduced website click rates to only 6% for display ads (Knowledge@Wharton 2017). As a result, a phenomenon called influencer marketing is increasingly common (Knowledge@Wharton 2017). Influencers are celebrities or “micro-celebrities” who use and have a high number of followers on social media—either in general or among a targeted population group (Carter 2016). The ubiquity of mobile devices has turned influencers into constant companions of the target audience; in 2022, 83% of more than 3,500 marketing and communications professionals viewed influencer marketing as effective (Geyser 2023). Marketers use Instagram, TikTok, Facebook, and other social media platforms to foster product engagement and to acquire brand ambassadors (i.e., influencers who are paid to endorse brands or promote products). According to the aforementioned survey of marketers, nearly 75% of brands track sales from influencer campaigns, with 55.5% of brands using TikTok, 50.8% using Instagram, 42.1% using Facebook, and 38.3% using YouTube as their network of choice for influencer marketing campaigns globally. Instagram’s engagement rates range from 0.95% per follower for macro-influencer or celebrity accounts with over 100,000 followers to 4.2% for micro-influencer accounts with fewer than 5,000 followers. TikTok’s largest macroinfluencer accounts with over 1 million followers average 10.3% engagement, and small accounts with 1,000–5,000 followers garner 15.0% engagement (Geyser 2023).

“Brand communities” (i.e., online social groups that are engaged in a product beyond just use) established on social media enhance customer–product and customer–brand engagement, as well as customer–company and customer–customer relationships (Laroche et al. 2013). The plethora of influencer marketplaces (e.g., Famebit.com) enables marketers to find social media celebrities and influencers whose followers are the target population for the brand (Knowledge@Wharton 2017).

In brief, influencer marketing offers tailored or targeted exposure to potential consumers who are susceptible to or already interested in the product category in which the brand operates, and as a result, consumers will likely pay attention (Brown and Hayes 2008). Additionally, influencer marketing can be used to target specific communities, including the Black or African American community, with tobacco messages. For instance, in a study examining tweets about little cigars and cigarillos from October 2014 to April 2015, Kostygina and colleagues (2016b) found that 17% of account users (representing 318,893 accounts) posting about little cigars and cigarillos were influencers. Influencers were often hiphop artists or those with Twitter accounts that were tied to the rap music community.

In addition to influencer marketing, sponsored content and native advertising have emerged as new ways to reach targeted audiences to generate interest in products (Wojdynski and Evans 2015; Escobedo et al. 2020b). Wojdynski and Evans (2015, p. 157) use the terms sponsored content and native advertising interchangeably to describe “any paid advertising that takes the specific form and appearance of editorial content from the publisher itself.” This includes advertorials (paid advertising content in the format of an editorial or objective news article), editorial content, brand journalism and blogs, and incentivized user- or consumer-generated product reviews and social media posts or location check-ins. Another example of sponsored content is the posting of selfies featuring a product or using a backdrop with product branding, often without explicit acknowledgment of the presence of the promotional content or disclosure of brand sponsorship. For example, an analysis of smoking imagery from Instagram, a photo-sharing social media platform, used tobacco- and e-cigarette-related text tags to identify more than 2 million relevant image posts. Content analysis of a sample of 8,000 of these image posts found that “smoking selfies” were the dominant image type. Such user-generated content was most often created by college-aged individuals and women, with most appearing to depict individuals of White race (Cortese et al. 2018). Although these posts were not explicitly tagged as advertising content, 40% of the posts included brand names or logos. Another study of Instagram posts with the hashtag vaping (#vaping) collected more than 500,000 images in a 5-month period in 2019 and found that images portraying people had the most engagement in the form of likes and comments and were more commonly posted by personal rather than business users (Ketonen and Malik 2020). Because new and emerging marketing strategies aim to leverage consumer-generated content, it has been challenging for researchers to clearly differentiate enthusiastic consumer-generated messages or opinions from sponsored content. As a result, few studies to date have measured the amount or impact of tobacco advertising and marketing content versus content posted from individual accounts (Huang et al. 2014). Thus, sponsored content and native advertising raise novel regulatory concerns and surveillance challenges for tobacco control researchers and programs that monitor tobacco industry practices concerning the marketing and promotion of cigarette and noncigarette tobacco products.

#### Digital Marketing

Beyond social media platforms, digital marketing has also been found to be widespread and associated with youth tobacco use. The 2021 NYTS documented that 43.9% of youth overall reported exposure to tobacco marketing through the Internet, with non-Hispanic Black youth reporting higher average levels (49.2%) of exposure to such marketing (Gentzke et al. 2022). In the 2014 NYTS, in adjusted analyses, exposure to e-cigarette ads at high or medium levels over the Internet showed a dose-response relationship with higher odds of current e-cigarette use (Dai and Hao 2016). Several studies using data from the PATH Study have found that engagement of youth with online tobacco marketing (e.g., watching videos about tobacco products online, signing up for e-mail alerts, playing online games) is associated with a higher incidence of initiating tobacco use (Soneji et al. 2017, 2018; Choi et al. 2020), increased frequency of tobacco use (Soneji et al. 2018), progression to using multiple tobacco products (Soneji et al. 2018), and a lower incidence of tobacco cessation (Soneji et al. 2018). Online engagement with tobacco marketing at baseline was also associated with higher odds of past-30-day use of cigarettes, e-cigarettes, cigars, smokeless tobacco, and hookah 1 year later (Choi et al. 2020). In another analysis of 2013–2014 (Wave 1) and 2014–2015 (Wave 2) data from the PATH Study, Soneji and colleagues (2019b) found that the percentage of youth who had engaged in at least one form of online tobacco marketing had increased from 8.7% to 20.9%. Notably, engagement with online tobacco marketing has been associated with increased (a) susceptibility to smoking (a measure of the likelihood of initiating smoking) (Pierce et al. 1995) and experimentation (Pierce et al. 1998; Soneji et al. 2017) among people who had never used tobacco and (b) probability of established smoking (Choi et al. 2001) or e-cigarette use (Clendennen et al. 2020) in the future.

Online banner and video ads have emerged as a digital alternative to print ads, usually appearing in news and entertainment publications. In an analysis of all online banner and video advertisements in the United States and Canada for tobacco products during a 1-year period in 2012–2013, two studies found that online banner and video advertising was a tactic used mainly to advertise e-cigarettes and cigars rather than conventional cigarettes, with some of this advertising offering unproven claims about benefits to health (Richardson and Vallone 2014; Richardson et al. 2015b). Later, Padon and colleagues (2017) analyzed a sample of video ads for e-cigarettes that were available as of August 2016. All of the ads in this study contained some content that was appealing to youth, with frequent emotional messages, including associating vaping with happiness, sex, and success. More than half of the video ads featured animation. Most of the ads (88%) appealed to the value of e-cigarettes over cigarettes, and 44% of the ads mentioned health (Padon et al. 2017).

In August 2016, the deeming rule effectively prohibited marketing of e-cigarettes with unsubstantiated modified risk claims (Federal Register 2016). In a content analysis of retail websites for e-cigarettes conducted in 2011–2012 (before the adoption of the deeming rule in 2016), Grana and Ling (2014) revealed that health claims and messages about smoking cessation that were unsupported by scientific evidence were frequently used to promote and sell e-cigarettes. A longitudinal study examining 288 websites for retailers of e-cigarettes before (2013–2014) and after (2016–2017) finalization of the deeming rule found that, although the marketing of products with claims such as “healthier than smoking” significantly declined during this period, more than half (52.4%) of e-cigarette retailer websites contained a health claim in the later period (Hsu et al. 2018). Additionally, no reduction was seen in the use of direct cessation claims (i.e., that e-cigarettes can help people quit smoking); these claims were present on 10.1% of websites in 2013–2014 and on 11.1% of websites in 2016–2017 (Hsu et al. 2018). Additionally, in a systematic review of literature about e-cigarette marketing communication messages by channel published between 2003 and 2019, cessation and health-related benefits were the most commonly reported marketing communication messages (each cited in 31 out of 41 studies included in the review; 75.6%) (Lyu et al. 2022). During summer 2020, Swisher International and John Middleton, a subsidiary of Altria, which makes Swisher Sweets and Black & Mild cigarillos, deployed the “#blacklivesmatter” hashtag and other racial-equity messaging in social media marketing (Heley et al. 2023).

Product price promotions are also prevalent on websites of retailers. For example, one study of online e-cigarette retailers found that more than half of the websites offered promotions or discount coupon codes at checkout, 23% offered loyalty or reward programs, and 11% offered discounts for new customer referrals (Mackey et al. 2015).

The relationships between e-cigarette advertising and e-cigarette use and cigarette advertising and cigarette use in both the online and traditional advertising environments are similar for both U.S. adults and adolescents. Agaku and colleagues (2017), who conducted a longitudinal study of the relationship between receptivity to e-cigarette advertisements and e-cigarette use among a sample of U.S. adults who did not use cigarettes or e-cigarettes at baseline, found that receptivity to e-cigarette advertisements at baseline was associated with greater odds of e-cigarette use at follow-up. Among U.S. middle and high school students participating in the 2014 NYTS, exposure to e-cigarette marketing on the Internet, in print, at retail stores, in movies, or on TV increased the likelihood of ever use of e-cigarettes, current use of e-cigarettes, and susceptibility to use e-cigarettes (Mantey et al. 2016). Further, as the number of channels of exposure to e-cigarette marketing increased, the likelihood of use and susceptibility also increased (Mantey et al. 2016). Another study of the 2014 NYTS also found that exposure to e-cigarette marketing via the Internet was associated with increased odds of perceiving e-cigarettes to be less harmful and less addictive than cigarettes, perceived likelihood of trying an e-cigarette soon, and e-cigarette use (Pu and Zhang 2017). Cruz and colleagues (2019a) found that California adolescents who never smoked but were exposed frequently to cigarette ads through the Internet or in stores were more likely to initiate cigarette smoking 16 months later, and those who had never smoked hookah but were exposed to hookah marketing in stores were more likely to initiate hookah use. Similarly, adolescents who never used e-cigarettes but were exposed to e-cigarette ads on the Internet, outdoors, or through stores were more likely to initiate e-cigarette use (Cruz et al. 2019a). Importantly, researchers have argued that marketing materials for e-cigarettes should not include implied and overt health claims, the presence of doctors on websites, celebrity endorsements, or the use of characterizing flavors (Grana and Ling 2014). However, this study predated the deeming rule in 2016,^1^ which extended FDA’s authority to all categories of products that met the statutory definition of a tobacco product, meaning “any product made or derived from tobacco that is intended for human consumption, including any component, part, or accessory of a tobacco product …” (Federal Register 2016, p. 28976). Importantly, marketing such tobacco products with unsubstantiated health claims is prohibited by federal law and may be subject to FDA enforcement under the Federal Food, Drug & Cosmetic Act (Federal Register 2016).

Beyond these overall associations between advertising and tobacco use, researchers are beginning to examine how differences in exposure to online tobacco advertising may contribute to tobacco-related health disparities. Among adolescents 14–17 years of age in the 2014–2015 PATH Study, engagement with online tobacco marketing in the past year was higher for female LGB youth (37.2%), male LGB youth (30.5%), and transgender youth (35.1%) compared with straight female (22.9%) or straight male (21.3%) youth (Soneji et al. 2019a). Additionally, Hispanic and non-Hispanic Black youth had higher odds of engaging with online tobacco marketing compared with non-Hispanic White youth (adjusted odds ratio [aOR] = 1.31 and aOR = 1.42, respectively). In the 2015 NYTS, Papaleontiou and colleagues (2020) found few differences in youth exposure to tobacco advertisements or promotions overall by race and ethnicity. However, the prevalence of exposure to advertising for conventional tobacco products via the Internet was higher among non-Hispanic Black youth (20.4%) than among Hispanic (15.3%), non-Hispanic White (13.3%), and non-Hispanic Asian (8.9%) youth; confidence intervals overlapped between non-Hispanic Black youth and youth of other or multiple races (17.6%). For e-cigarette advertising and promotions via the Internet, youth of other or multiple races reported higher exposure (16.5%) than non-Hispanic White (10.9%) and non-Hispanic Asian (6.1%) youth; confidence intervals overlapped for youth of other or multiple races, non-Hispanic Black youth (14.6%), and Hispanic youth (13.1%) (Papaleontiou et al. 2020). Carroll and colleagues (2020) found that American Indian and Alaska Native and Non-Hispanic Black adults reported higher exposure to e-mail marketing for tobacco products than did non-Hispanic White adults; non-Hispanic Asian adults reported lower exposure than that reported by non-Hispanic White adults. Additionally, commercial tobacco use was higher among adults who reported exposure to tobacco ads, mail, and email marketing. However, the study did not find interactions between marketing exposures and race and ethnicity on tobacco use outcomes. Still, research overall is lagging and does not yet fully explain how this increasingly complex media and communication landscape affects different populations of youth and young adults relative to their attitudes, beliefs, susceptibility, experimentation, initiation, and patterns of use across the diversifying landscape of tobacco products (Huang et al. 2019). Clearly, however, the promotion of tobacco products through digital and social media is proliferating and may contribute to disparities in exposure to tobacco product marketing and tobacco use.

### Promoting Tobacco Products on Mass Media

Beyond social and other online media, numerous other forms of tobacco marketing continue to play a role in promoting tobacco use, including marketing through television, magazines, and movies. These approaches constitute both direct marketing attempts and indirect advertising, such as through depictions of tobacco use in movies.

#### Television

In terms of direct approaches, despite the digitization of the media landscape, television is still an important platform for news and information (Guttmann 2023; Navarro 2023). Television programming and advertising used to be distributed exclusively on broadcast television, but today television advertising encompasses both broadcast and digital streaming services.

Unlike conventional cigarettes, e-cigarettes have been subject to fewer marketing restrictions, providing e-cigarette companies with an opportunity to advertise to a broad television audience that includes millions of youth (Duke et al. 2014; USDHHS 2016). In 2019, several television broadcasters agreed to voluntary restrictions on advertising for e-cigarettes, potentially limiting such mass media exposures to marketing for these products (Booker 2019). Despite this, the Federal Trade Commission reported that e-cigarette companies spent $93.8 million on television advertising in 2019 (Federal Trade Commission 2022). Using data from the 2016 NYTS, Marynak and colleagues (2018) estimated that 37.7% of U.S. middle and high school students had been exposed to e-cigarette advertisements on television. In a study conducted from 2014 to 2015, television was the most frequently reported source of exposure to e-cigarette advertising for all age groups of adolescents (74.9%), young adults (70.7%), and adults over age 26 (66.9%) (Wagoner et al. 2019). Among adolescents, the remaining sources of exposure in descending order were retail, digital marketing, radio, print, and billboards (Wagoner et al. 2019). Farrelly and colleagues (2015) found that the top four highest rated e-cigarette ads among young people that aired during 2013 and 2014 included unproven health claims and youth-appealing themes, such as freedom and independence and using these products in locations where using cigarettes is prohibited as key messages (Farrelly et al. 2015). Marketing of newly deemed products, including e-cigarettes, with modified risk claims was prohibited when FDA asserted regulatory authority through the deeming rule in 2016 (Federal Register 2016).

Additionally, differences may exist in which groups are likely to be exposed to television advertising. In a national sample of adults conducted in 2012, among those who had heard of e-cigarettes in this early time period, television was the most common source, with 61.1% of Black respondents having heard of e-cigarettes on television compared with 47.4% of White, non-Hispanic respondents and 40.1% of Hispanic respondents (Zhu S-H et al. 2013). Exposure to ads about e-cigarettes on television was lower among young adults, 18–24 years of age (41.6%) and adults 65 years of age and older (57.3%). Furthermore, people with a high school education or less were more likely to have heard about e-cigarettes on television than people with greater levels of educational attainment (51.8% vs. 45.3%) (Zhu S-H et al. 2013). On the basis of data from the 2021 NYTS, exposure to marketing or advertising for any tobacco product on television, through streaming services, or through movies was higher among non-Hispanic Black youth (39.7%) than among non-Hispanic White youth (27.8%), Hispanic youth (31.9%), and youth of other, non-Hispanic races (27.7%) (Gentzke et al. 2022). Furthermore, exposure to e-cigarette advertising on television, streaming, and through movies was higher among non-Hispanic Black youth than youth of other races and ethnicities (Gentzke et al. 2022).

To assess the effects of the tobacco industry’s marketing practices on youth and young adults, several scholars have examined these populations’ quantity of exposure to television advertisements and evaluated their receptivity to these practices while also assessing their susceptibility to start using tobacco products. Duke and colleagues (2014) observed large increases for youth and young adults in the exposure to television advertisements for e-cigarettes from January 2011 to September 2013 and suggested a probable increase in the awareness and use of e-cigarettes in this population. Using data from the NYTS, e-cigarette experimentation and recent use doubled among U.S. middle and high school students during 2011–2012 (CDC 2013). Using data from Wave 1 of the PATH Study (2013–2014), Pierce and colleagues (2017) reported that a large proportion of U.S. adolescents who had never used any tobacco product, including e-cigarettes, were receptive to tobacco advertising, with the highest receptivity to ads for e-cigarettes followed by ads for cigarettes and smokeless tobacco. Additionally, among these youth who never used tobacco, the highest recall was for television advertising for e-cigarettes. Further, the study found that receptivity to advertising for each noncigarette tobacco product was associated with susceptibility to smoking conventional cigarettes. In addition, compared with non-Hispanic White youth who never used tobacco, non-Hispanic Black youth, Hispanic youth, and youth of other races had higher odds of susceptibility to any tobacco use.

#### Magazines

Magazine advertising continues to be an important channel for marketing tobacco products. NCI Tobacco Control Monograph 19 summarized a large body of literature on targeted marketing to a variety of audiences in magazines and concluded that “[p]aid tobacco advertising tends to suppress or reduce news coverage of tobacco-related issues, particularly in magazines” (NCI 2008, p. 15). Tobacco advertising in magazines has not only increased protobacco marketing cues but also suppressed coverage of the health hazards of smoking for magazine readers, particularly in magazines directed at women (Warner et al. 1992; USDHHS 2001). Reports from the Federal Trade Commission (2023a,b) show that the tobacco industry spent more than $9.6 million on magazine advertising for cigarettes and smokeless tobacco in 2022, although this amount has declined substantially from prior years (NCI 2008; Federal Trade Commission 2021a,b). Additionally, e-cigarette manufacturers spent $5.2 million on magazine advertising in 2018, increasing to $13 million in 2019 and declining to $2.7 million in 2020 (Federal Trade Commission 2022). Among U.S. adults in the 2013–2014 National Adult Tobacco Survey, for each additional e-cigarette advertisement in magazines to which an adult was exposed in the past 6 months, there was a 0.07-percentage-point increase in current cigarette smoking (Ali et al. 2021). However, there was no association between this advertising exposure and ever or current e-cigarette use. Among young adult college students in Texas who were followed for 2 years, after controlling for other covariates, those with higher exposure to tobacco ads in magazines used more tobacco products compared with those with less exposure (Loukas et al. 2021). In interaction models with the survey wave, young adults with greater exposure to tobacco ads reported a slower decline in the number of tobacco products they used over time (Loukas et al. 2021).

In an experimental study, Pokhrel and colleagues (2019) found that exposing young adults to social enhancement-themed ads for e-cigarettes (i.e., ads containing messages that promote e-cigarette use as a means of attaining a better social life or social status or self-image) in magazines and online communicated messages of reduced harm from e-cigarettes relative to cigarettes. These ads affected young adults’ explicit and implicit attitudes relative to control ads of everyday items collected from real-world sources in 2014 and, as a result, increased their susceptibility to using e-cigarettes.

As depicted in Figure 5.2, the tobacco industry continues to use magazines to market specific tobacco products to specific populations. Richardson and colleagues (2015a) examined advertisements for menthol cigarettes from June 2012 to February 2013 and found that 61% of print advertisements for Newport brand cigarettes featured at least one African American model. Further, of the 20 magazines in which Newport ads were placed, 6 had greater than 10% African American readership, such as Jet, Ebony, and Essence. A study by Banerjee and colleagues (2015) provided a content analysis of tobacco print ads in various magazines, finding that these magazines (Jet, Ebony, and Essence) exclusively ran ads for cigarettes, including menthol brands Newport and Camel Crush. However, more general interest magazines, such as Entertainment Weekly or Rolling Stone, included ads for cigarettes, e-cigarettes, and snus (Banerjee et al. 2015).

The populations targeted by magazine ads from the tobacco industry include but are not limited to:

- People who identify as LGBTQI+ and have been targeted with ads for menthol and nonmenthol cigarettes (e.g., in Out magazine in 2016) (Trinkets & Trash 2016a, b, e) and e-cigarettes (e.g., in Out magazine in 2019) (Banerjee et al. 2015; Trinkets & Trash 2019e).
- Armed services personnel and veterans who have been targeted with ads for smokeless tobacco (e.g., “Copenhagen salutes our soldiers, our veterans, our heroes”)—which appeared in multiple men’s magazines in 2021 (Trinkets & Trash 2021a) and in periodicals, such as Military Times magazine in 2005 (Haddock et al. 2008)—and cigar advertisements (e.g., in American Way magazine (Trinkets & Trash 2013b)
- Hispanic readers, who have been targeted with ads for smokeless tobacco (Dave and Saffer 2013), menthol cigarettes (e.g., in Latina magazine in June 2016), and little cigars (e.g., in People Spanish in 2019 and 2020) (Trinkets & Trash 2016d, 2019b, 2020b).
- Women, with differentiation in the specific products marketed to them based on their income and race and ethnicity. One study examining e-cigarette and cigarette advertising in women’s magazines found that, unlike cigarette marketing, which was equally distributed across magazines targeting higher and lower income readerships, more than 75% of e-cigarette advertising was featured in magazines for higher income audiences (Basch et al. 2016). This same study found that 64% of cigarette ads were in women’s magazines targeted to Black or Latina audiences, and only 18% of e-cigarette ads were in magazines for this demographic.

#### Price Promotions

As described previously, the tobacco industry targets marketing in retail stores and promotes cheaper tobacco products and price promotions to populations of lower SES and minoritized racial and ethnic groups. Reduced price marketing for tobacco products extends well beyond the retail environment. For example, Tessman and colleagues (2014) found through the NYTS that 13.1% of middle and high school youth had been exposed to coupons from a tobacco company through the mail or a digital communication or on a tobacco package in the past 30 days; among those who lived with a person who used tobacco, 20.0% were exposed to tobacco coupons. Exposure to coupons through the mail or on packages was more common among non-Hispanic White students than among non-Hispanic Black students, and exposure to digital coupons from a tobacco company was more common among Hispanic students and non-Hispanic students of other races than among non-Hispanic White students. However, overall exposure to coupons was comparable among all assessed racial and ethnic groups. The study did not report exposure to coupons by type of tobacco product (Tessman et al. 2014). In another study from the Midwest, Choi and Forster (2014) found that people with lower levels of educational attainment were more likely than those with greater levels of educational achievement to receive cigarette coupons through the mail. Elsewhere, Rose and colleagues (2018) conducted a longitudinal study of youth who received tobacco-related coupons and found that female youth, nonurban youth, and youth with higher levels of internalized mental health symptoms were most likely to receive coupons. In addition, the study found that having received coupons was associated with higher odds of (a) tobacco use among people who had never used tobacco, (b) trying a new tobacco product, and (c) current tobacco use at 1-year follow-up (Rose et al. 2018). A systematic review of 27 studies examining exposure to coupons and risk for tobacco initiation and cessation found that receipt and redemption of tobacco product coupons were most prevalent among young adults, people in minoritized sexual orientation and gender identity groups, people with lower educational attainment, and people with higher tobacco use intensity (Liber et al. 2021). The review found some evidence across studies that coupon receipt was associated with increased odds of tobacco initiation among people who never used tobacco and that coupon receipt or redemption was associated with lower odds of cessation among people who used tobacco (Liber et al. 2021).

In addition to conventional tobacco products, youth are frequently exposed to price promotions from the tobacco industry for e-cigarettes (USDHHS 2016; Tattan-Birch et al. 2022; Chen-Sankey et al. 2023; Elhabashy et al. 2023). E-cigarette companies use marketing strategies that are similar to the strategies used to promote conventional cigarettes (Walley et al. 2019). Moran and colleagues (2019a) noted, however, that ads for conventional cigarettes were more likely than ads for e-cigarettes to use discounts and sweepstakes to increase brand loyalty, and ads for e-cigarettes were more likely than ads for conventional cigarettes to target new consumers by modeling the use of the products and highlighting their qualities.

#### Promotional Events and Sampling

Although event sponsorship by specific brand names of cigarettes and smokeless tobacco products was prohibited by the Master Settlement Agreement and by FDA under the Tobacco Control Act, tobacco companies can still sponsor events using their own corporate names. Altria reported sponsoring the Richmond Jazz Festival in 2017 and was the leading sponsor of that festival in 2018 (Richmond Jazz Festival at Maymont 2018; Altria n.d.a). The 2018 Richmond Jazz Festival included several prominent African American musicians (Richmond Jazz Festival at Maymont 2018). Event sponsorship also extends to non-cigarette tobacco products. Ganz and colleagues (2018) found that Swisher Sweets, a popular cigar brand among African American young adults who smoke and among young people who smoke (Glasser et al. 2016), promoted the Artist Project on its website in 2017; the Artist Project included “Swisher Sweets Pack Nights” and “Convenience Store Sessions.” The Pack Nights were sponsored concerts performed by emerging musical artists; concerts were held in major cities across the United States, including Atlanta, Detroit, Houston, and Los Angeles. The Convenience Store Sessions included video recording artists performing in convenience stores with substantial tobacco branding observable by viewers; videos were then placed on Swisher Sweets’ website (Glasser et al. 2016).

E-cigarette manufacturers also sponsor events (e.g., sporting events, music concerts, comedy shows) (McCarthy 2014; USDHHS 2016), thereby enhancing the visibility and potentially the use of e-cigarettes, especially among young audiences. For example, according to data from Wave 2 of the PATH Study, youth and young adults who had never used tobacco and who reported past-30-day exposure to e-cigarette marketing at events like fairs, festivals, or sporting events in Wave 2 of the PATH Study were more likely to have experimented with e-cigarettes by Wave 3 of the study—defined as having ever used e-cigarettes, even one or two times—than those who were not exposed to such marketing (youth aOR = 1.72; 95% CI, 1.09–2.73; young adult aOR = 4.21; 95% CI, 1.49–11.96) (Chen-Sankey et al. 2019).

Elsewhere, Branstetter and colleagues (2015) conducted focus groups with adults in the rural Appalachian area of Pennsylvania to better understand how this population group perceives tobacco-related messages in the media. The study found that participants specifically recalled tobacco company sponsorship at sporting or other events, including the National Association for Stock Car Auto Racing (NASCAR) and other auto-racing sponsorships, as well as promotional tents and other activities at races and concerts (Branstetter et al. 2015). Furthermore, focus group participants recalled seeing tobacco promotional advertisements at gas stations and convenience stores, as well as seeing tobacco use in movies and by celebrities that were “encouraging of tobacco use” (Branstetter et al. 2015).

The tobacco industry has also marketed tobacco products at bars frequented by members of the LGBTQI+ community, historically providing free drinks, cigarette samples, and prizes (Leibel et al. 2011). Fallin and Davis (2016) examined the tobacco industry’s promotional events in LGBTQI+ bars in San Jose, California, from 2013 to 2015, noting, for example, that representatives from Philip Morris provided “buy one, get one free” coupons for tobacco products and handed out free e-cigarettes and replacement cartridges. Under the Tobacco Control Act, FDA prohibited free cigarette samples in 2010 (Federal Register 2010). Free e-cigarettes and replacement cartridges became subject to the same prohibition on free samples upon adoption of the deeming rule in 2016 (Federal Register 2016).

#### Movies

In addition to traditional direct advertising, indirect marketing—such as depictions of tobacco use in movies—can strongly influence the initiation of smoking among youth and young adults. NCI Tobacco Control Monograph 19 concluded that “[t]he total weight of evidence from cross-sectional, longitudinal, and experimental studies … indicates a causal relationship between exposure to depictions of smoking in movies and youth smoking initiation” (NCI 2008, p. 12). The 2012 Surgeon General’s report further noted that “[t]he evidence is sufficient to conclude that there is a causal relationship between depictions of smoking in the movies and the initiation of smoking among young people” (USDHHS 2012, p. 6). One study of a cohort of children, 9–12 years of age at baseline (in 2002–2003), who were from Vermont and New Hampshire and followed for 3 years found that youth were exposed to 149.6 instances of smoking in movies on average over a 3-year period, including 40.7 occurrences at baseline, 53.4 occurrences at Wave 2, and 55.9 occurrences at Wave 3 (Titus-Ernstoff et al. 2008). In modeling, exposure to instances of smoking in movies at baseline (Wave 1) was significantly associated with prediction of smoking initiation by Wave 3; this prediction was not improved by adjusting for additional exposures at Wave 2 and Wave 3, indicating that exposures in early childhood to instances of smoking in movies is similar in importance to exposures that occur closer to the time of smoking initiation (Titus-Ernstoff et al. 2008). Additional research has found that the number of scenes in movies that include smoking rises with each increase in movie rating, such as from Rated G (general audiences) to Rated PG (parental guidance suggested) to Rated R (restricted) (Tynan et al. 2019; Polansky et al. 2020). In a meta-analysis of 17 studies (9 cross-sectional studies, with a median sample size of 4,919, and 8 longitudinal studies, with a median sample size of 2,298), higher exposure to smoking in movies was associated with a 93% increase in the risk of ever trying smoking in the cross-sectional studies and a 46% increase in the risk of smoking initiation in the longitudinal studies (Leonardi-Bee et al. 2016). In 1998, the Master Settlement Agreement prohibited paid product placement for cigarette brands in movies produced in the United States. Morgenstern and colleagues (2017) evaluated depictions of smoking in Hollywood movies and found a marked decrease in the number and duration of smoking depictions in movies in the 11 years after the Master Settlement Agreement compared with the 11 years before the agreement. Nonetheless, about half of top-grossing films from U.S. movie studios in 2018 continued to include tobacco use and imagery, with nearly one-third of youth-rated films including tobacco incidents (Tynan et al. 2019).

Various studies have examined depictions of smoking in movies targeted to particular populations. For example, among the 81 U.S. movies released from 2000 to 2011 identified as having LGBTQI+ themes or characters, tobacco use was depicted in 87% of a random sample (n = 45) of these movies, with, on average, four occurrences of tobacco use depicted every hour (or about once every 15 minutes) (Lee et al. 2014). Elsewhere, in a national study of initially nonsmoking adolescents (n = 2,341), Black adolescents had greater exposure to smoking in both Black-oriented and mainstream movies compared with teenagers from other racial and ethnic groups (Dal Cin et al. 2013). For teenage viewers who were Black, exposure to smoking in mainstream movies was not associated with smoking initiation, but exposure to smoking in Black-oriented movies was associated with smoking initiation. However, for other adolescents, exposure to smoking in both mainstream and Black-oriented movies was associated with smoking initiation (Dal Cin et al. 2013). Finally, an earlier study (Wilkinson et al. 2009) found that, for Mexican-born U.S. youth from Houston, Texas, increasing exposure to smoking in movies was associated with increased smoking initiation. However, for U.S. born youth, a ceiling effect was observed, in which smoking initiation increased with increasing exposure to smoking in the movies, but then plateaued at high levels of exposure (Wilkinson et al. 2009). As such, country of birth moderated the association between exposure to smoking in movies and smoking initiation.

### Critical Differences Between Promoting Tobacco Products on Mass Media Versus Social Media

Communication to the public through the media reflects and shapes population-level understanding of important issues, including health-related issues. As information media and communication technologies evolve, health-related information is expanding to include social media platforms, such as Twitter, Instagram, and Facebook. Although the link between tobacco marketing through traditional media channels and tobacco use is well-established, the nature and mechanisms of the effects of social media are understudied (Depue et al. 2015; Hebert et al. 2017). Additionally, researchers have identified a need for more studies on how exposure to information and misinformation about tobacco products on social media affects attitudes toward tobacco products and tobacco use specifically among populations experiencing tobacco-related health disparities (Tan and Bigman 2020). Searches on mechanisms of effect revealed few studies that examined the differences between tobacco marketing on social media versus other media channels and in relation to specific groups. Thus, this section focuses primarily on differences in how social media versus mass media is theorized to work in general. Additional research is needed to better understand whether these theoretical relationships work similarly or differently for populations experiencing tobacco-related health disparities.

In a mass media environment, messages are typically encountered passively (Obermiller 1985; Southwell et al. 2002), but on social media, engagement can be both active and passive (Ramirez et al. 2002; Liang and Scammon 2013). As with other types of content, social media enables consumers to search for, engage with, and access information or to produce and share content about tobacco and related products, promotions, and opportunities to purchase these products.

A substantial amount of literature differentiates between the effects of passive exposure and active information-seeking behaviors (Johnson 1997; Niederdeppe et al. 2007). Information-seeking can lead to more intensive or enduring behavior change than passive exposure because active seeking involves greater scrutiny and depth of information processing (Slater 1997; Kahlor et al. 2002; Dutta-Bergman 2004). Research conducted in 2013 indicated that sharing information about tobacco products, notably e-cigarettes, was not a common practice among the general population, but it was far more common among young adult populations, and those who used tobacco were five times more likely than those who did not use tobacco to report sharing information about e-cigarettes (Emery et al. 2014). A nationally representative, cross-sectional study of youth and young adults, 13–25 years of age, found that (a) 18- to 25-year olds were more likely to share information about tobacco and e-cigarettes than 13- to 17-year-old youth, and (b) those who intended to use or currently used cigarettes were significantly more likely than their counterparts to share information about e-cigarettes (Jeong 2018). A longitudinal study of youth and young adults found that actively seeking information about e-cigarettes was associated with e-cigarette use 6 months later (Yang et al. 2019). Another study found that, among a cohort of young adults from Southern California, those who had shared pro-tobacco-related content on Twitter were more likely to use cigarettes and any tobacco products than were young adults who did not share such content (Unger et al. 2018). Finally, Sawdey and colleagues (2017) found positive and significant associations between viewing e-cigarette posts from peers on social media and both lifetime and current e-cigarette use among a convenience sample of college students.

Health campaigns on social media may be undermined by protobacco proponents, leading to a blunting of intended effects. Research on the potential for social media health messages to backfire is of particular importance for tobacco countermarketing campaigns because social media messages are subject to fewer regulations and often contain misinformation, making it difficult to monitor and improve them (Tan and Bigman 2020; Kong et al. 2022b). Further, tobacco companies use sophisticated strategies, such as Twitter bombing (i.e., spamming or posting messages from multiple accounts to flood conversations with one perspective), astroturfing (i.e., masking commercial message sources as organic or grassroots accounts), and hashtag hijacking (i.e., using the hashtag of a tobacco countermarketing campaign to signal opposition to the message, program, or policy initiative)—all of which contribute to potential undermining of countermarketing media campaigns (Harris et al. 2014; Allem et al. 2017a). For example, in response to a media campaign by the California Department of Public Health on the harms of e-cigarette use called Still Blowing Smoke, a nonprofit organization formed in response to the campaign launched its own pro-e-cigarette advocacy campaign called NOT Blowing Smoke. NOT Blowing Smoke had a higher tweet volume than Still Blowing Smoke over the campaign period, and 92% of tweets referencing the campaigns were coded as pro-e-cigarette (Allem et al. 2017b). In another campaign in 2014, the Chicago Department of Public Health used the hashtag #ecigtruths to disseminate messages about e-cigarettes before a city council vote to regulate e-cigarettes as tobacco products. An analysis of Twitter messages about the campaign found that 80% of messages using the hashtag expressed opposition to regulation, 14% included aspects indicative of astroturfing, and few Twitter users who were tweeting on the subject were from the Chicago area (Harris et al. 2014).

### Marketing and Media Summary

Studies reaffirm the conclusions of prior Surgeon Generals’ reports that a causal association exists between tobacco marketing and the initiation and use of tobacco products, especially for youth (Lovato et al. 2011; Singh et al. 2016a; Pierce et al. 2018; Chen-Sankey et al. 2019; Cruz et al. 2019a). Similar relationships have also been found for tobacco marketing exposure through television (Pierce et al. 2017), online marketing (Soneji et al. 2017, 2018; Choi et al. 2020), magazines (Loukas et al. 2021), and exposure to tobacco in the movies (Titus-Ernstoff et al. 2008; Leonardi-Bee et al. 2016) and among young adults through pro-tobacco content on social media (Clendennen et al. 2020). Marketing for e-cigarettes is also associated with e-cigarette initiation and use (Mantey et al. 2016; Agaku et al. 2017; Camenga et al. 2018). Social media marketing has some unique features relative to traditional media marketing, including enhanced targeting, searchability of content, and the use of influencers (Geyser 2023). The rapid growth and near ubiquitous use of social media platforms has increased accessibility to tobacco-related information, including promotions and depictions of use or implied use, which abounds on such platforms as Twitter, YouTube, and TikTok (Huang et al. 2014, 2016; Cranwell et al. 2015; Rutherford et al. 2022; Sun et al. 2023). Emerging research indicates that, similar to traditional media, seeking and sharing information about tobacco products on social media is associated with tobacco use (Unger et al. 2018; Yang et al. 2019). However, in the United States, there are few restrictions on marketing for tobacco products other than cigarettes and smokeless tobacco, and diverse groups of young people are exposed to pervasive and often stealthy marketing for tobacco products on digital and online media channels.

An abundance of literature documents how traditional tobacco product marketing tactics may contribute to disparities in tobacco use (USDHHS 1998; NCI 2008). However, few studies have documented how new marketing tactics, which increasingly incorporate both traditional media and social and digital media marketing in a complex media market, may contribute to disparities in the use of tobacco products. However, several factors are likely at play in the rapidly changing media environment, including (1) differential access to and use of media platforms across groups; (2) targeted marketing to specific groups across media platforms; and (3) differential impacts of marketing on tobacco use across groups, which is described in greater detail in the following section.

#### Differential Access To and Use of Media

First, research shows that access to digital media, including social media, has grown substantially in recent years. Although most youth and young adults can access the Internet and social media through smartphones, regardless of SES and geographic area of residence, there are racial and ethnic differences in social media use. African American and Hispanic adults use social media at higher rates than White adults, and almost constant social media use is more common among Black and Hispanic teens than among White teens (Auxier and Anderson 2021; Vogels et al. 2022), which could result in potential racial and ethnic disparities in exposure to tobacco product-related marketing via social media.

#### Targeted Marketing to Specific Groups Across Media Platforms

Tobacco marketing is broadly available online, and marketing for noncigarette tobacco products is available through traditional media, such as television, because of differential regulatory oversight for such products as e-cigarettes (Duke et al. 2014; USDHHS 2016). Such marketing narrowly targets certain racial and ethnic groups. For example, African American audiences are frequently targeted with tobacco marketing and advertising across media platforms through music promotions, influencers, magazines, messages about menthol cigarettes, and tobacco industry websites (Cruz et al. 2010; Richardson et al. 2014, 2015a; Ganz et al. 2018; Escobedo et al. 2020b). Exposure to targeted marketing messages online is also higher among Hispanic youth and Black youth than among non-Hispanic White youth (Soneji et al. 2019a). Additional research is needed that examines media and non-retail marketing strategies that specifically target Asian American and Pacific Islander, American Indian and Alaska Native, and multiracial and multiethnic people (Carroll et al. 2020). Additionally, as noted previously, evidence suggests that e-cigarette advertising in women’s magazines was initially targeted to higher income and White women (Basch et al. 2016). In 2019, several television broadcasters agreed to voluntary restrictions on advertising for e-cigarettes—potentially limiting such mass media exposure to marketing for these products (Booker 2019). Additionally, FDA began authorizing the marketing of some e-cigarette products through the Premarket Tobacco Product Application (PMTA) process. These authorizations include restrictions on digital advertising and television and radio advertising (FDA 2021b). Research should continue to examine the potential for differential exposure to mass media marketing among different populations, including for tobacco products with PMTA authorization, to better understand the potential impact of these marketing restrictions, the industry’s responses, and the unanticipated effects.

There are also disparities in exposure to tobacco product marketing by sexual orientation and gender identity. People who identify as LGBTQI+ are exposed to more tobacco marketing and engage with such content on social media at higher rates compared with non-LGBTQI+ people (Emory et al. 2019; Soneji et al. 2019a). Differences in marketing exposure may also exist within LGBTQI+ populations, with increased exposure documented among bisexual women compared with gay or heterosexual women and even greater disparities in exposure among bisexual men and women from some racial and ethnic groups (Tan et al. 2021).

Despite having less access to the Internet and social media, populations with lower SES experience higher levels of exposure to tobacco product marketing (Zhu S-H et al. 2013; Assari 2020). An analysis of data from the PATH Study found that coupon receipt was associated with increased odds of progression to current smoking, continuing smoking, and progression to or continuation of daily smoking (Choi et al. 2020). Receipt of tobacco coupons also appeared to be more prevalent among persons with lower levels of educational attainment than among those with higher levels of educational attainment (Choi and Forster 2014; Osman et al. 2019; Assari 2020; Liber et al. 2021).

#### Differential Impacts of Marketing on Tobacco Use Across Groups

Several studies have found interactions between demographic characteristics and marketing exposure on tobacco product use outcomes; however, these interactions vary by type of exposure and population. For example, among participants in Wave 1 of the PATH Study who never used tobacco products, African American youth and those with a lower SES had greater recall of ads related to cigarettes and cigars (Moran et al. 2019b). Also, compared with non-Hispanic White and Hispanic youth, African American youth were significantly more likely to report using e-cigarettes because the e-cigarette advertising appealed to them. Tobacco use disparities related to tobacco marketing are likely driven more by differential exposure to targeted marketing among racial and ethnic and lower SES populations than by differential effects of marketing exposure on tobacco use for these groups, but the research in this area is not robust. More research is needed to examine differences in exposure to tobacco marketing and the resulting impact on tobacco use attributable to the intersection of different identities, such as one’s race and ethnicity, sexual orientation and gender identity, and SES. Furthermore, disparities arising from targeted marketing and advertising may be made worse by inequities in communication and in media literacy. However, additional research is needed that examines the roles of inequities in communication (such as differences in the ability to generate, access, disseminate, share, and act on information) and media literacy with respect to the impact of tobacco product marketing and advertising on use, initiation, and cessation.

A limitation of the literature is that few studies investigated the link between commercial tobacco marketing and engagement on social media with individual tobacco use or tobacco-related health disparities. The large and growing amount of promotional content for tobacco products that is available online presents a pressing need to monitor this content and to develop strategies to curb digital marketing for tobacco products on social media. However, the methodologic basis needed to systematically audit and engage with the tobacco-related content on these sites is only beginning to develop (Kim et al. 2017; Chew et al. 2021, 2022). Research is warranted that examines how tobacco companies use digital marketing and promotional content to target certain populations and ultimately contribute to tobacco product-related disparities in the rapidly changing social media environment.

Finally, given the swift innovation in the tobacco marketplace, continued surveillance is needed to track (a) marketing trends and use patterns of newer and/or rapidly changing tobacco products—such as e-cigarettes, heated tobacco products, and nicotine pouches—among diverse populations and (b) the impact of these emerging products on tobacco-related health disparities.

## Tobacco Industry Tactics to Counter Tobacco Prevention and Control Efforts

Aligning with the 1998 Surgeon General’s report, this section reviews evidence on the tobacco industry’s political, legal, economic, corporate, and community tactics to counter tobacco control efforts among minoritized racial and ethnic groups and other populations that have been disproportionately affected by tobacco-related health disparities in the United States. It specifically examines how the tobacco industry has supported organizations serving several disparate communities, including diverse minoritized racial and ethnic groups and sexual orientation and gender identity groups (e.g., those who identify as LGBTQI+), people in certain geographic locations (e.g., rural areas), and people with behavioral health conditions. Such approaches have been named as part of the “vector” in the HAVE model, which focuses on the marketing activities of the tobacco industry (Cruz 2009; Giovino et al. 2009).^2^

### Literature Review Methods

A literature search was conducted in the PubMed and Web of Science electronic databases for studies published in English between 2008 and 2021 that focused on the tobacco industry’s political, economic, corporate, and community responses to tobacco control among racially and ethnically diverse groups and other specific populations impacted by tobacco-related health disparities. Studies that examined tobacco companies’ responses to tobacco control efforts before 2000 were largely excluded. Appendix 5.1 presents a list of search terms. Other potentially relevant articles were identified from the reference lists of articles found in the literature search. The search was supplemented with literature nominated by colleagues and reviewers with relevant expertise and from additional resources, such as relevant news articles and reports about funding from tobacco companies. On the global scale, additional information about such tactics is available from the University of Bath’s Tobacco Tactics website (http://tobaccotactics.org).

### Political Tactics of the Tobacco Industry

The tobacco industry uses both direct and indirect or grassroots political lobbying and other tactics that counter tobacco control efforts (Ulucanlar et al. 2016; Tangcharoensathien et al. 2017). Tobacco companies have a documented history of promoting their agenda through the use of campaign contributions, donations to the political parties of legislators, and gifts and payments to policymakers (USDHHS 1998; Campaign for Tobacco-Free Kids 2020; Action on Smoking & Health 2021; OpenSecrets 2021). During the 2019–2020 election cycle, Political Action Committees for tobacco companies contributed more than $1.5 million to federal political candidates (Campaign for Tobacco-Free Kids 2020). Lobbying on behalf of tobacco companies occurs throughout the United States at the local, state, and national levels. In 2021, 918 lobbyists or lobbying firms for the tobacco industry were registered at the state level and 236 lobbyists were registered at the federal level, of whom more than 78% were former government employees (Action on Smoking & Health 2021).

Tobacco lobbyists often work to oppose effective tobacco control policies, and tobacco companies contribute to the campaigns of political candidates (Givel and Glantz 2001; Morley et al. 2002; Bero 2003; Levin 2015). In addition, some major tobacco companies and/or their foundations make contributions to high-profile political organizations and Congressional caucuses that advocate on behalf of people from racial and ethnic groups and LGBTQI+ rights groups, among many others (Altria n.d.b). In addition to funding political organizations, tobacco companies have selectively donated to African American politicians when legislative decisions about menthol cigarettes were pending (Levin 2015). According to an analysis of records from the Center for Responsive Politics, Lorillard, Inc. contributed to the campaigns of half of all African American members of Congress in 2014 when a policy decision to add menthol to the list of characterizing flavors was being considered (Levin 2015). Lorillard had a vested interest in blocking menthol restrictions because at that time, the company manufactured Newport brand cigarettes, which is the most popular brand of menthol cigarettes in the United States (Sharma et al. 2016) and which is used by the majority of African American people who smoke (Villanti et al. 2016). In 2015, Reynolds American finalized the acquisition of Lorillard, including its Newport brand, and divested some brands to Imperial Tobacco (Mickle and Brent 2015).

As noted in the 1998 Surgeon General’s report, the tobacco industry also uses indirect or grassroots lobbying to promote its agenda among the general electorate (USDHHS 1998; Ulucanlar et al. 2016). Figure 5.3 displays several present-day examples of indirect or grassroots lobbying, including in-store displays and direct-to-consumer emails encouraging the public to oppose cigarette tax increases and federal and state restrictions on menthol cigarettes.

Furthermore, the tobacco industry contributes financial support to advocacy groups, including groups whose positions align with the tobacco industry’s agenda. For example, in 2010, representatives from groups with “a history of tobacco industry ties” (Cheyne et al. 2014, p. e57, citing Yerger and Malone 2002) argued against banning menthol cigarettes before a public meeting of the Tobacco Products Scientific Advisory Committee (TPSAC), a congressionally mandated advisory committee of FDA (Healy 2010; Cheyne et al. 2014). Arguments against a ban on menthol cigarettes advanced by both industry participants and participants representing the aforementioned groups during the TPSAC meeting included concerns that a ban would start an illicit market and result in greater police activity in communities where menthol cigarettes were preferred (Healy 2010; Cheyne et al. 2014; Levin 2017). Such arguments continue to be used to oppose policies that prohibit menthol cigarettes, including FDA’s proposed product standard. However, many Black leaders have rejected these arguments and tactics, for example:

- The National Association for the Advancement of Colored People (NAACP) stopped accepting tobacco industry funds more than two decades ago as a result of the industry’s targeted marketing strategies. In a 2022 letter to HHS and White House leadership, NAACP’s president Derrick Johnson “reject[ed]” the “tobacco industry’s message and strategy presented by a few Black leaders [that] prohibiting menthol cigarettes would be discriminatory.” Instead, he noted that “the failure to prohibit the sale of menthol cigarettes and products would be discriminatory” (National Association for the Advancement of Colored People 2022a, b).
- Rev. Horace Sheffield, a prominent Black pastor and civil rights leader in Detroit, said he declined more than $200,000 from R.J. Reynolds to oppose a menthol cigarette ban and was told that others had received as much or more for doing so. Sheffield said in an interview with the Bureau for Investigative Journalism that “[the offer] was between $200,000 and $250,000 one time, plus additional money going forward if I would actually say, ‘I thought about it, I’m on the wrong side’”(Stockton 2023).
- In 2023, members of the Congressional Black Caucus Health Braintrust wrote to the FDA Commissioner in support of a product standard to prohibit menthol cigarettes and reinforcing that “[the] FDA cannot and will not enforce against individual consumers for possession or use of a menthol cigarette or flavored cigars. … For too long, tobacco companies have been enabled to promote menthol cigarettes to the Black community …” (Congressional Black Caucus Health Braintrust 2023a, b).

### Legal Tactics of the Tobacco Industry

Tobacco companies also engage in legal actions to contest legislation and policy aimed at regulating the tobacco industry (Ulucanlar et al. 2016). With respect to FDA’s regulation of tobacco products, this includes, but is not limited to, constitutional challenges to multiple provisions of the Tobacco Control Act (Discount Tobacco City & Lottery, Inc. v. United States 2012; Keighley 2012) and the 2016 deeming rule, statutory and constitutional challenges to FDA’s 2011 text-and-image warnings for cigarette packaging (R.J. Reynolds Tobacco Co. v. U.S. Food & Drug Administration 2012), text warnings for cigars and pipe tobacco under the 2016 deeming rule (Cigar Association of America v. U.S. Food & Drug Administration 2020), 2020 text-and-image warnings for cigarettes (R.J. Reynolds Tobacco Co. v. U.S. Food & Drug Administration 2022), and statutory and constitutional challenges to FDA’s application of the Tobacco Control Act to e-cigarettes under the 2016 deeming rule (Nicopure Labs, LLC v. U.S. Food and Drug Administration 2019; Big Time Vapes v. FDA 2020; Curfman 2021).

Figure 5.3 Examples of (a) indirect or grassroots lobbying to oppose tobacco prevention and control initiatives and (b) community engagement efforts of the tobacco industry

A Indirect or grassroots lobbying

Source: Email from Altria’s Marlboro brand cigarettes in May 2022 asking consumers to help stop a menthol ban by leaving comments on a website (Trinkets & Trash 2022b).

Source: Signage attached to a window of a liquor store in 2022 in New Jersey urging consumers to speak to lawmakers about not banning menthol cigarettes (Trinkets & Trash 2022c).

Source: Instagram post by Backwoods brand cigars in 2022 that linked consumers to a form where they could comment against FDA’s ban on cigar flavors (Trinkets & Trash 2022a).

Source: Email from Camel brand cigarettes in 2021 asking recipients to visit a website to voice their opposition to tax increases on all nicotine products (Trinkets & Trash 2021d).

B Community engagement

Source: Instagram post by ITG Brands’ Dutch Masters brand cigars in June 2020 showing the company’s support for Black Lives Matter and Black populations (Dutch Masters 2020).

Source: Instagram post by Swisher Sweets brand cigars in July 2020 that provides an update about the company’s inclusion, diversity, and transformation strategy in support of Black Lives Matter (Trinkets & Trash 2020a).

Source: Screenshot from Altria’s website in 2022 about its Race & Equity Initiative. Started in 2020, the initiative aims to address systemic racism and advance social and economic equity (Altria n.d.c).

Source: Screenshot from Reynold American’s website in 2023 describing the Santa Fe Natural Tobacco Company Foundation and highlighting the foundation’s financial assistance to “172 organizations serving Native American communities” to “support the preservation, promotion, and advancement of American Indian self-sufficiency and culture in the United States” (Reynolds American n.d.).

After conducting a detailed review of the scientific evidence, FDA’s Tobacco Products Scientific Advisory Committee issued a lengthy report in 2011, concluding that prohibiting the sale of menthol cigarettes would benefit the public’s health. Two manufacturers of menthol cigarettes, Lorillard and R.J. Reynolds Tobacco, then sued FDA, alleging conflict of interest for three members of the advisory committee (Dooren 2011). U.S. District Judge Richard J. Leon issued rulings in the tobacco companies’ favor in 2012 and again in 2014 and ordered FDA not to use or rely on the report (Clarke 2016). These rulings were overturned by the U.S. Court of Appeals for the D.C. Circuit in 2016 (Clarke 2016).

The tobacco industry also acts at the state and local levels by contesting laws that regulate the sale of flavored tobacco products (Lester and Gagosian 2017). For example, policymakers passed ordinances prohibiting the sale of any flavored noncigarette tobacco product in New York City (adopted in October 2009) and Providence, Rhode Island (approved in January 2012) (City of Providence 2012; Brown et al. 2019). The tobacco industry filed lawsuits against both regulatory policies, but the ordinances were upheld after going through an appeals court process (Lester and Gagosian 2017). The industry has contested similar local policies in California, Illinois, Massachusetts, Minnesota, and Pennsylvania and in other Rhode Island communities (e.g., see Public Health Law Center [n.d.a]).

Additionally, R.J. Reynolds and tobacco industry trade groups challenged, through ballot measures at the state and local levels, laws prohibiting the retail sale of certain flavored tobacco products in California. Proponents of the California statewide flavored tobacco referendum included an attorney for Reynolds American Inc., and a lobbyist for the National Association of Tobacco Outlets and the Vapor Technology Association. Voters upheld the referendum (Agenbroad et al. 2020; Raymond 2022).

Preemption (which is described in more detail in Chapter 7) refers to the ability of a higher level of government to block or override the action of a lower level of government. Major tobacco companies and affiliated retailer trade groups have repeatedly gone to court to argue that the federal Tobacco Control Act preempts state and local restrictions on menthol and other flavored tobacco products (Twinamatsiko 2022). As of late 2022, this argument had been rejected by every court to consider it (Twinamatsiko 2022). The U.S. Supreme Court declined to hear R.J. Reynolds’ challenges to flavor restrictions on these grounds in California in 2022, in Los Angeles County in 2023, and again in California in 2024 (Raymond 2022, 2024).

The tobacco industry also has a history of using litigation to deter the adoption of certain policies by local jurisdictions that are unable to defend against lengthy and costly legal challenges, even if such challenges are ultimately unsuccessful in court (Nixon et al. 2004). NCI Tobacco Control Monograph 21 discusses these approaches in more detail in the international context, concluding that, “The tobacco industry also uses the threat of litigation, with its attendant costs, and lobbying campaigns to deter governments from advancing tobacco control policies, especially in low- and middle-income countries” (NCI and WHO 2016, p. 16).

### Economic Tactics of the Tobacco Industry

One of the most effective ways to prevent tobacco initiation and reduce consumption is to increase the price of tobacco products (Chaloupka et al. 2011; NCI and WHO 2016). Increasing the price of cigarettes may also be an effective way to reduce disparities in smoking behavior because several studies have shown that people from some racial and ethnic groups, people with substance use and mental health conditions, and people from lower income groups who smoke are more sensitive to price increases than are White people who smoke and those in higher income groups (Farrelly et al. 2001; Ong et al. 2010; Golden et al. 2016). Chapter 7 discusses the impact of price increases on disparate groups. The tobacco industry uses multiple strategies to avoid the imposition of tax increases, including front groups (i.e., seemingly independent organizations that are directed and funded by the tobacco industry in an effort to influence policy and public opinion), direct lobbying, and publicity campaigns (Apollonio and Bero 2007; Smith et al. 2013; Action on Smoking & Health 2021). Once tax increases are passed, to counter the reduced consumption among groups sensitive to price hikes, the tobacco industry uses price discounting marketing strategies (e.g., coupons) to reduce the cost of tobacco products for consumers, which, as noted in Chapter 4, are often received and redeemed by people from various disparate groups.

Tobacco companies also use multiple strategies to mitigate the impact of tax increases, such as stockpiling products, relabeling them, offering coupons, and overshifting and undershifting prices (Ross et al. 2017). Stockpiling, also known as forestalling or frontloading, is a method of oversupplying the marketplace before a tax increase goes into effect. This strategy is used to postpone the effects of a tax increase by (a) increasing product sales before the tax increase goes into effect and (b) reducing sales after the increase. The tobacco industry also relabels tobacco products in response to tax increases. For example, although roll-your-own tobacco and pipe tobacco differ in terms of physical characteristics, tobacco manufacturers relabeled roll-your-own tobacco as pipe tobacco in 2009 following a Federal excise tax on roll-your-own tobacco that created a large tax disparity between these two products (Tynan et al. 2015; Ross et al. 2017). As such, pipe tobacco was taxed at a lower rate than roll-your-own tobacco, resulting in a shift in sales to pipe tobacco during this time (Tynan et al. 2015).

Tobacco companies strategically use coupons to mitigate the effects of taxes. In one specific example, shortly before a 62-cent-per-pack increase in the national cigarette excise tax went into effect in 2009, Philip Morris USA contacted consumers—including women, youth, and other price-sensitive groups—and provided them with coupons to purchase cigarettes at a cost below the retail price (Ross et al. 2017). Additional details on price promotions can be found in the “Influences of the Tobacco Retail Environment” section of this chapter.

The term overshifting refers to raising the retail price of cigarettes by more than the tax increase (Ross et al. 2017). Overshifting can be used selectively on higher priced brands so that discount brands can remain at lower prices while company profits are maintained. However, overshifting has the potential to undermine the pro-equity impact of excise taxes because discount brands typically purchased by price-sensitive people with lower incomes who smoke are offset less due to cigarette excise tax increases, while premium and ultra-premium brands targeted to people with higher incomes who smoke are offset more due to tax increases (Henriksen et al. 2019). Thus, this practice attenuates the primary intent of increasing tobacco taxes, which is to discourage cigarette purchases and reduce tobacco use (Evans et al. 1999; Henriksen et al. 2019). Brock and colleagues (2016) reported that the tobacco industry overshifted prices on premium-brand cigarettes—Marlboro Gold and Camel Blue—in response to a 2013 tobacco tax increase in Minnesota.

In the practice of undershifting, the industry lowers the retail price in response to a tax increase to maintain price-sensitive consumers. Price increases for tobacco products are timed so that consumers can gradually adjust to price fluctuations (Ross et al. 2017). Tobacco companies can increase profits by raising prices for less price-sensitive consumers. In addition, companies can lower prices through the use of coupons to those who are more price sensitive, such as young adults who smoke and people of lower income levels who smoke (Levy et al. 2019).

Tobacco companies also change quantities in packages to influence the behavior of consumers. In a review of historical tobacco industry documents from 1980 to 2009, Persoskie and colleagues (2019) reported that tobacco companies had extensive consumer research on the use of smaller packages for tobacco products—which can be sold at lower per-package prices—as a marketing tool to promote the trial of a product and to offset tobacco tax increases. Larger packages, on the other hand, can have higher per-unit value and suggest an economical option to consumers. Federal regulations require packs of cigarettes to contain a minimum number of 20 cigarettes, but no such minimum pack size exists for cigars and other combusted tobacco products. Delnevo and colleagues (2017) found that cigar companies take advantage of small package sizes (e.g., packages containing only two or three cigars) to attract consumers to low-priced tobacco products and ultimately facilitate their continued smoking behavior.

Cruz and colleagues (2010) described price-related marketing strategies in “focus communities” used by La Tanisha Wright, who was a former trade marketing and controlling manager for tobacco manufacturer Brown & Williamson. Wright later became a tobacco control advocate. Wright disclosed that Brown & Williamson used the term focus communities to hide “allusions to variations in marketing due to race and ethnicity;” focus stores served predominantly lower income, urban, Black communities with high sales of menthol cigarettes (Cruz et al. 2010, p. S147). Wright, who worked for Brown & Williamson in Detroit, Michigan, and Atlanta, Georgia, from 2001 to 2004, reported providing premium tobacco contracts to focus stores. These contracts allowed focus stores to sell their tobacco products at lower prices than in non-focus stores. For example, focus stores could receive manufacturer rebates that let them reduce the retail price of cigarettes by up to $1.50 per pack for an entire year, and non-focus stores would receive rebates that let them reduce the retail price of cigarettes by only $0.50 per pack for only 6 months. Wright reported that focus stores also received more allocations of coupons and that these coupons provided an incentive for consumers to use a particular tobacco product (Cruz et al. 2010).

According to Brown-Johnson and colleagues (2014), in the late 1990s and early 2000s, Philip Morris Companies, Inc., and R.J. Reynolds developed credit cards to attract lower income female consumers. Several credit cards were piloted, including the Marlboro Unlimited Card, Marlboro Club Card, and Camel Gas Cash card. The Camel Gas Cash card was preloaded with $15 that could be redeemed for gasoline. Teams at Philip Morris proposed the Pioneer Card, with the target population for the card described by the company as “unbanked” (i.e., people without a checking or savings account) (Federal Deposit Insurance Corporation 2022). This population consisted mainly of urban, lower income Latino and African American women with below-average educations.

### Corporate Social Responsibility Tactics of the Tobacco Industry

In the 1990s, the tobacco industry received extensive negative news coverage linked to multiple lawsuits and the release of previously confidential documents that described and exposed its marketing, advertising, scientific research, and political practices (Hirschhorn 2004). To promote a positive image, the tobacco industry embraced a corporate social responsibility model and campaign, which included the allocation of funding to corporate philanthropy (Hirschhorn 2004; NCI 2008; Tesler and Malone 2008; Fooks et al. 2013). As described by Luo and Bhattacharya (2006), the corporate social responsibility model includes a company’s activities related to a perceived commitment and accountability to stakeholders and society. The largest U.S.-based tobacco companies (Philip Morris USA, Altria, and Reynolds American, Inc.) all appeared to embrace the corporate social responsibility model (McDaniel et al. 2016).

Today, tobacco companies share and promote information about their corporate social responsibility practices through a large online presence and in the news media. McDaniel and colleagues (2016) reported that in February 2014, Altria, Philip Morris USA, Lorillard, and Reynolds American, Inc., had 24, 40, 15, and 50 corporate social responsibility web pages, respectively. These web pages described several focus areas of corporate social responsibility, including funding for the arts, reducing hunger or poverty, philanthropy in the local community, education, disaster relief, smoking cessation, youth tobacco prevention, and domestic violence, among others. Philip Morris USA and Altria’s web pages included a goal of contracting with women- and minority-owned businesses as evidence of responsible supply chain management. Later, McDaniel and colleagues (2018) found that U.S. media coverage of social responsibility activities by tobacco companies often occurred at the local level (e.g., through local newspapers) and in the South, which is home to headquarters of several tobacco companies. In a content analysis of 649 news items, the majority (77.2%) conveyed a positive impression of the tobacco industry. Coverage of funding for education and arts, domestic violence programs, disaster relief, food aid, and tobacco company partnerships with local governments or tobacco company employees volunteering was most likely to have a positive slant toward the tobacco industry. Conversely, coverage of funding for youth smoking prevention, other youth issues, and disease prevention was least likely to have a positive slant, and the slant of coverage about funding for “minority issues” and the environment was statistically indistinguishable from that of donations in general (McDaniel et al. 2018).

Several studies have focused on the corporate social responsibility activities of Philip Morris USA and its parent company, Altria (Hirschhorn 2004; Tesler and Malone 2008; Smith et al. 2016). Hirschhorn (2004) reported that during the litigation that resulted in the Master Settlement Agreement, Philip Morris USA developed the Philip Morris in the 21st Century campaign, also known as PM21, a public relations strategy to improve the company’s image by emphasizing its social responsibility activities. Later, Tesler and Malone (2008) reported that, based on tobacco industry documents (Burson-Marstellar 2000), target groups for the PM21 campaign were opinion leaders, suburban parents, members of Generation X, Hispanic people, active moms, and women from diverse racial and ethnic groups. Philip Morris, which had previously focused on market success, had changed its narrative for both the public and its employees to that of a “good corporate citizen” (Hirschhorn 2004; Tesler and Malone 2008). Although the PM21 campaign yielded more positive media coverage for tobacco companies than did the social responsibility activities of the tobacco industry in general (McDaniel et al. 2018), analyses of internal company documents reveal that Philip Morris’s then new responsibility-oriented narrative was unpersuasive to company employees (McDaniel and Malone 2015).

In 2017, the Foundation for a Smoke-Free World (FSFW) was established with funding from Philip Morris International (The Lancet 2017; Yach 2017). According to Derek Yach, the inaugural president of FSFW, the aim of FSFW is to eliminate cigarette smoking worldwide and help people who smoke switch to reduced-risk tobacco products (The Lancet 2017; Yach 2017). Yach also argued that a harm-reduction approach is the best way to reduce tobacco-related harm (Yach 2017). Philip Morris International committed $1 billion in funding to FSFW over a 12-year period (The Lancet 2017) and subsequently modified FSFW’s founding agreements to allow for more interaction between Philip Morris International and the foundation (Cohen et al. 2021). An analysis of FSFW’s 2019 tax return revealed that nearly one-third of its $80 million annual budget paid salaries, public relations, and legal fees; many grants were for public relations and advocacy projects (Cohen et al. 2021). In a review of peer-reviewed and pre-print articles funded by FSFW, Legg, Clift and Gilmore concluded that the publications were “safe” research “which distract attention from industry harms, frame industry products as part of the ‘solution’ and promote interventions that minimise damage to product sales” (Legg et al. 2023, p. 4). In 2023, after accepting a final grant of $122.5 million from Philip Morris, FSFW announced that its agreement with Philip Morris International was terminated (Tobacco Tactics 2023). Then, in December 2023, FSFW changed its name to Global Action to End Smoking, Inc. (New York State, Department of State, Division of Corporations n.d.).

The corporate social responsibility activities of tobacco companies have often been criticized. For example, the World Health Organization (2003, p. 1) stated that corporate social responsibility among tobacco companies is an “inherent contradiction,” and Tesler and Malone (2008, p. 2123) reported that Philip Morris’s image makeover activities “explicitly linked philanthropy to government affairs and used contributions as a lobbying tool against public health policies.” The United Nations General Assembly (2012, p. 5) recognized a “fundamental conflict of interest between the tobacco industry and public health.” Moreover, several studies have argued that improving the tobacco industry’s image through social responsibility activities at the corporate level allows the industry to access policymakers, make political allies, and affect legislation on tobacco control (Tesler and Malone 2008; Apollonio and Malone 2010; McDaniel et al. 2016). The World Health Organization (2017) more recently noted that the FSFW and similar entities are “working to further the interests [of the tobacco industry]” and stated that “if [Philip Morris International] were truly committed to a smoke-free world, the company would support [strengthening implementation of the Framework Convention on Tobacco Control policies]. … Instead, [Philip Morris International] opposes them. … WHO will not partner with the Foundation.”

### Community Tactics of the Tobacco Industry

Tobacco companies have long promoted themselves in racial and ethnic communities and other underserved communities by sponsoring organizations and events. Beginning in the 1990s, researchers highlighted the role of such tactics in promoting tobacco products to a variety of groups, including African American and Latino populations and women, by making an “enormous investment in civic, social, political, media, and fraternal organizations serving these respective populations” (Robinson et al. 1992, p. S24). The 1998 Surgeon General’s report on tobacco use among four racial and ethnic groups also highlighted the tobacco industry’s long-term practice of providing employment opportunities to specific population groups and making financial donations to causes, community-serving groups, and political organizations that advocate for social justice issues (USDHHS 1998). Research, including from industry documents, suggests that the tobacco industry has gotten involved with communities to normalize tobacco use, develop brand loyalty, and build opposition to health-protective tobacco control policies (Yerger and Malone 2002; Portugal et al. 2004; Offen et al. 2008; Wailoo 2021; Yerger 2022). For example, Brown & Williamson (B&W), the original manufacturer of Kool brand cigarettes, explained the intent of this association with particular transparency: “Association with a national civil rights organization can be viewed, in its most positive sense, as an endorsement of Brown & Williamson and its products to the minority community. … Clearly, the sole reason for B&W’s interest in the black and Hispanic communities is the actual and potential sales of B&W products within these communities and the profitability of these sales”(MAB 1984, p. 1).

The sections that follow provide examples of the involvement of tobacco companies in Black or African American, Hispanic or Latino, American Indian and Alaska Native, Asian American and Pacific Islander, sexual orientation and gender identity, and rural population groups; with people experiencing homelessness; and with people with behavioral health conditions. Figure 5.2 provides present-day examples of these tactics, and Figure 5.4 provides examples of how the tobacco industry uses cultural appropriation and racial and ethnic stereotyping in commercial tobacco advertising.

Although this section focuses on tobacco industry activities in communities, it is important to acknowledge innovative efforts that have emerged from communities to counter these activities, for example:

- Minnesota’s Keep Tobacco Sacred campaign and California’s Stop the Sale of Our Image: Don’t Buy the Lie campaign leverage messages about Indigenous community assets to reclaim Native culture and restore the traditional meanings of tobacco (North Coast Journal 2003; D’Silva et al. 2018; National Native Network n.d.).
- Organizations that serve LGBTQI+ populations, such as the Bradbury-Sullivan LGBT Community Center in Allentown, Pennsylvania, collaborate with public health partners, such as the American Lung Association, to promote smokefree Pride events (Bradbury-Sullivan LGBT Community Center n.d.).
- The Center for Black Health & Equity initiated “No Menthol Sunday,” an annual faith-based observance day to engage faith communities in discussions about the impact of menthol cigarettes on community health (The Center for Black Health & Equity 2023).
- In 2023, the Hawaii Department of Health, Coalition for a Tobacco-Free Hawai’i, and Hawai‘i Public Health Institute launched the Stronger Together campaign, noting that “the people of Hawai‘i are fighting back and holding Big Tobacco accountable for the harm it causes.” The campaign includes messages from tobacco industry documents about industry targeting of Native Hawaiian people, LGBTQI+ populations, people with lower incomes, people with behavioral health conditions, and youth (Hawaii State Department of Health n.d.).

Figure 5.4 Examples of cultural appropriation and stereotyping in commercial tobacco advertising

Source: Email from American Spirit brand tobacco products in November 2021 inviting recipients to sign up for The Spirit Circle to receive text messages about promotions for the company’s products (Trinkets & Trash 2021e).

Source: Ad for R.J. Reynolds Tobacco’s Camel Crush brand mentholated squeezers coopting Native Hawaiian imagery (date unknown) (Stanford Research into the Impact of Tobacco Advertising n.d.b).

Source: Starbuzz hookah tobacco in Exotic Asian Persuasion flavor in 2016 (Stanford Research into the Impact of Tobacco Advertising 2016a).

#### Black or African American Communities

For decades, the tobacco industry has provided financial support to African American community and civil rights organizations (Robinson et al. 1992; USDHHS 1998; Yerger and Malone 2002). According to industry documents, these efforts were often conducted to build opposition to health-protective tobacco control policies, such as cigarette excise taxes and bans on provisions of free samples of cigarettes, and to build support for protobacco policies (Yerger and Malone 2002; Yerger 2022). Similarly, tobacco companies have developed relationships with leaders and governing committees of African American organizations. For example, Altria reported providing charitable contributions in 2021 to several African American business and civil rights groups, educational entities, and arts organizations (Altria n.d.b).

For many decades, the tobacco industry was a commercial sponsor for the African-American press at a time when resources were scarce, and the industry used the resulting platform to embed the use of cigarettes within African-American communities and Black identity (Jones and Perry Jr 2022). From the Civil Rights era onward, the tobacco industry has supported the National Newspaper Publishers Association (formerly the National Negro Publishers Association [NNPA]), a group representing more than 200 African American newspapers and more recently electronic media outlets, with advertising and NNPA-related sponsorships, in turn garnering media support for industry positions (McCandless et al. 2012; Mangun and Perry Jr 2020). Marginal comments on one internal tobacco-industry document indicate that the industry provided such funding with the expectation of a quid pro quo (McCandless et al. 2012).

In 2016, Reynolds American, Inc., hosted a discussion titled “Panel Discussion, Criminal Justice Reform—Hosted by RAI Company” at the annual convention of the NNPA. A Black former congressmember and the former president of a national organization serving Black law enforcement were listed as part of this program. A year earlier, Reynolds American, Inc., had contributed $250,000 to the National Newspaper Publishers Association (Levin 2017). These exchanges could obscure a clear understanding of the impacts that may occur when proposed restrictions on—for example, menthol cigarettes and flavored cigars (FDA 2021a; Federal Register 2022a, b)—are finalized in diverse communities across the United States.

#### Hispanic American Communities

Hispanic American people are the largest ethnic group in the United States. Like other industries, tobacco companies have focused a substantial percentage of their marketing efforts on this diverse, growing, and geographically clustered group. In market research, R.J. Reynolds determined that brand choices among Hispanic people were influenced by SES, experiences of discrimination, and “not feeling wanted and appreciated, ‘which in turn created’ a strong need for recognition” (Iglesias-Rios and Parascandola [2013], p. e17, citing Research Resources [1988]; R.J. Reynolds Records Collection [1989]). The company leveraged these findings to inform advertisements that incorporated the Spanish language and Hispanic culture. R.J. Reynolds also sought to “establish a presence and a positive image within the Hispanic community” by participating in Cinco de Mayo celebrations, sponsoring local events, and performing outreach to such Hispanic community leaders; Hispanic civic, educational, and social organizations; and Hispanic members of Congress (Iglesias-Rios and Parascandola 2013, p. e20).

For 2021, Altria, which is headquartered in Richmond, Virginia, reported making charitable contributions to several Hispanic-serving business, civic, and educational organizations (Altria n.d.b).

#### American Indian and Alaska Native Communities

Tobacco companies have also built relationships with American Indian and Alaska Native organizations, providing sponsorships and charitable contributions to their community organizations. Lempert and Glantz (2019) found that, in 2001, Philip Morris granted $476,161 to an initiative that promoted healthy lifestyles among American Indian youth in Arizona, Montana, New Mexico, Oklahoma, and South Dakota.

The tobacco industry has misappropriated American Indian imagery in its marketing tactics since at least the 1930s (D’Silva et al. 2018). Tobacco industry documents reveal that the industry marketing has incorporated the cultural significance of ceremonial tobacco to “validate” commercial tobacco (D’Silva et al. 2018). These tactics were heightened by the emergence of the Santa Fe Natural Tobacco Company (SFNTC) in 1982, maker of the American Spirit brand of “natural” cigarettes, which has coopted images of traditional headdresses and peace pipes on packaging (D’Silva et al. 2018). The SFNTC Foundation was founded in 1997 to provide grants to the American Indian community to “support the preservation, promotion, and advancement of American Indian self-sufficiency and culture in the United States” (Lempert and Glantz 2019; Reynolds American n.d.). As cited in D’Silva and colleagues (2018), facing criticism in 2000 about its misappropriation of American Indian imagery, SFNTC executives cited the company’s charitable giving, saying, “We’d like to think that we’re giving something back to these people in exchange for using this imagery” (Crellin 2000). As with the industry’s expectations of a “quid pro quo” for its financial support of the National Newspaper Publishers Association, such statements from tobacco industry executives provide insight into the industry’s transactional motives for corporate giving (McCandless et al. 2012).

In 2002, Reynolds American, Inc. acquired SFNTC (Lempert and Glantz 2019). According to a 2008 corporate social responsibility report from Reynolds American Inc., this foundation donated in 2006 and 2007 nearly $500,000 to American Indian and Alaska Native educational, cultural, arts, and civil rights organizations (Reynolds American 2009). The SFNTC Foundation remains active (Reynolds American n.d.).

#### Asian American and Pacific Islander Communities

Research is limited on the tobacco industry’s involvement in Asian American and Pacific Islander communities. An earlier study of tobacco industry documents found that industry representatives understood the importance of the Asian American and Pacific Islander market as early as the late 1980s. Native Hawaiians were specifically viewed as an important market for menthol cigarettes, as an industry document noted, “the menthol smoker in Hawaii seems to be the native” (All Ways Advertising 1985, p. 5). Philip Morris considered using “corporate goodwill” strategies to reach out to the Asian American and Pacific Islander communities via corporate contributions and sponsorships. In 1988, Philip Morris provided corporate sponsorship for various Asian American and Pacific Islander community-sponsored festivals, races, or concerts, many of which were open to people of all ages (Muggli et al. 2002). In its report about charitable contributions in 2021, Altria (n.d.b) reported giving to multiple foundations and organizations serving Asian populations and their business interests.

#### Sexual Orientation and Gender Identity Groups

The tobacco industry has targeted the LGBTQI+ community in multiple ways. The industry has not only advertised in magazines that market to this group, as described previously in this chapter, but has also positioned itself indirectly as a supporter of this community by touting the industry’s donations to organizations focused on addressing HIV/AIDS and its support for LGBTQI+ pride. In 2002, Philip Morris proclaimed itself, in an advertisement in PRIDE .02 (a U.S.-based gay pride magazine), as one of the largest corporate contributors to the fight against AIDS (Stevens et al. 2004).

Offen and colleagues (2008), who interviewed 74 leaders of LGBTQI+ organizations in the United States between 2002 and 2004, found that 22% reported accepting funding from the tobacco industry. These leaders noted the moral dilemma in taking money from the tobacco industry but also reported the fiscal need for funding, suggesting the importance of efforts to supplant tobacco industry financial support to LGBTQI+ causes with sustainable support from sources that do not profit from the sale of products that harm the health of community members. For 2021, Altria reported charitable contributions to multiple LGBTQI+-serving legal, business, and civil rights organizations (Altria n.d.b).

#### Rural Communities

Exposure to tobacco marketing via event sponsorships has been associated with increased risk of smoking (DiFranza et al. 2006). Before FDA banned tobacco company sponsorship of sports and entertainment events in 2010, as directed in the Tobacco Control Act, Ling and colleagues (2010) reported that tobacco companies sponsored sporting events, such as rodeos, to gain access to rural audiences. Rodeos are popular among children, and according to tobacco industry documents, an estimated 25–30% of attendees at rodeos are younger than 18 years of age (Ling et al. 2010). Additionally, from 1974 to 2009, before the acquisition of the U.S. Smokeless Tobacco Company (USSTC) by Altria Group, Inc. in 2009, the USSTC awarded more than $4 million in rodeo college scholarships (Morton 2009). USSTC was also a sponsor of the National Intercollegiate Rodeo Association College National Finals Rodeo competition, providing free samples of Copenhagen and Skoal smokeless tobacco at the event (Morton 2009; Ling et al. 2010).

More recently, Altria’s list of 2022 regional charitable giving includes donations to the organizations serving rural communities and farmers in multiple Southeastern states (Altria 2022).

#### People Experiencing Homelessness and Those with Behavioral Health Conditions

The tobacco industry has also targeted marketing toward people experiencing homelessness and people with behavioral health conditions (Apollonio and Malone 2005). For example, R.J. Reynolds’s Project SCUM (subculture urban marketing) initiative was aimed at “street people” and gay men in San Francisco (R.J. Reynolds Records Collection 1995). In a review of tobacco industry documents, Apollonio and Malone (2005) found that, in 1988, Philip Morris awarded a 2-year grant of $100,000 to the National Coalition for the Homeless, then requested that the Coalition for the Homeless in New York perform outreach to lawmakers to encourage them to focus on ending homelessness instead of focusing on passing smokefree indoor air laws. More recently, Altria’s list of 2022 regional charitable giving includes donations to organizations working to address homelessness and to provide or improve homes for veterans, first responders, and their families (Altria 2022).

People with behavioral health conditions—including any mental health conditions or substance use disorders in the past year—consume as much as 40% of cigarettes smoked by adults in the United States (Substance Abuse and Mental Health Services Administration 2013). Research into tobacco industry documents found evidence of indirect promotion of smoking to psychiatric patients and opposition to rules banning smoking in mental health facilities through financial support and ties to advocacy groups for patients with schizophrenia (Prochaska et al. 2008). Altria’s list of 2022 charitable giving (Altria 2022) identifies donations to organizations serving the behavioral health needs of LGBTQI+ individuals and providing physical and psychological rehabilitation services to U.S. combat veterans.

Although peer-reviewed research is lacking on the extent to which the tobacco industry’s ties to these populations persist, newer efforts to promote noncigarette tobacco products to people with behavioral health conditions have emerged. For example, as of 2022, the Arizona-based Vape A Vet project, a nonprofit organization supported by e-liquid manufacturer BRV Liquids, offered free e-cigarettes (including electronic smoking devices used to deliver cannabis) to veterans “to allow unfettered access to veterans wounded in battle and dealing with PTSD [posttraumatic stress disorder]” (Vape A Vet n.d.). Vape A Vet’s Twitter account shared branded content about available vaping products, and Twitter users posted testimonials about vaping, suggesting the promotional potential of engaging with the veteran community, particularly those with PTSD.

A systematic review found that people with PTSD show high levels of nicotine dependence and heavy tobacco use (Pericot-Valverde et al. 2018), suggesting they are an important priority population to reach with tobacco cessation treatments, including behavioral therapies and FDA-approved medications. However, tobacco products, including e-cigarettes, are not a safe or effective treatment for PTSD. Nicotine withdrawal is commonly accompanied by symptoms of anxiety and depression, and relief of these symptoms may be an important component of addiction among people who use tobacco products (USDHHS 2014). Furthermore, whereas cigarette smoking is associated with worse mental health symptoms and outcomes among people with behavioral health conditions, quitting smoking is associated with improvements in mental health (Prochaska et al. 2017).

### Tactics of the Tobacco Industry Summary

As also documented in the 1998 Surgeon General’s report, the tobacco industry has used political, legal, economic, corporate social responsibility, and community tactics to circumvent tobacco control efforts, including those intended to promote tobacco-related health equity. Tactics include direct lobbying through campaign contributions and donations to policymakers, sponsoring efforts to oppose tobacco control policies in ballot initiatives, and funding political organizations that represent the interests of minoritized groups. The industry also engages in legal tactics by contesting tobacco control legislation at the local, state, and federal levels (Ulucanlar et al. 2016).

Tobacco companies have used several economic strategies to mitigate the impact of tax increases on profits, including stockpiling, relabeling tobacco products, offering coupons, overshifting and undershifting prices, and changing quantities in packages (Tynan et al. 2015; Ross et al. 2017). These tactics undermine tobacco control efforts, such as tax increases, which are aimed at protecting populations that are already targeted by the industry. Further, to promote a positive image, the tobacco industry has embraced a corporate social responsibility model, which includes funding corporate philanthropy (Tesler and Malone 2008; Fooks et al. 2013).

Tobacco companies have promoted themselves in specific communities by funding and donating to various political groups and nonprofit organizations and by sponsoring organizations and events in Black or African American, Hispanic American, American Indian and Alaska Native, Asian American and Pacific Islander, and LGBTQI+ communities. The companies have also promoted themselves to people living in rural areas, people experiencing homelessness, and people with behavioral health conditions, including veterans. Research suggests that the tobacco industry donates to these communities to normalize tobacco use, develop brand loyalty, and build opposition to tobacco control policies that are intended to protect public health (Yerger and Malone 2002; Portugal et al. 2004; Offen et al. 2008). These community-level strategies and practices of the tobacco industry continue to exacerbate tobacco product-related disparities and inequities.

## Summary of the Evidence

This chapter applied the HAVE (Host-Agent-Vector-Environment) model (Figure 5.1) to examine multiple industry activities that encourage a social environment of normalized tobacco use patterns, which can differ by population group and neighborhood characteristics. The studies reviewed in this chapter demonstrate disparities in the tobacco retail environment (e.g., community-level retail density) and consumer or store environment (e.g., advertising, promotions, pricing). The density of tobacco retailers is greater in neighborhoods with higher percentages of Black and African American residents and lower income residents in urban areas across the United States. Mixed evidence also suggests that tobacco retailer density is also greater in neighborhoods with greater percentages of Hispanic or Latino residents. Advertisements for menthol-flavored cigarettes and for cigars and cigarillos are also common in neighborhoods with greater percentages of Black residents, youth, and residents of lower SES. The evidence also suggests that the price of cigarettes is lower in neighborhoods with higher percentages of minoritized racial and ethnic groups, youth, and lower income residents. These targeted marketing and advertising techniques can encourage experimentation and initiation of tobacco product use among people who have never used tobacco.

The evidence described in this chapter reaffirms the conclusions of previous Surgeon Generals’ reports that a causal association exists between tobacco marketing and the initiation and use of tobacco products, especially among youth. As communication technologies have evolved, the introduction of social media platforms—such as Twitter, Facebook, and Instagram—has caused a seismic shift in how the tobacco industry interacts with, recruits, and maintains consumers. Influencer marketing, sponsored content (e.g., advertorials, blogs, and brand journalism), and native advertising (i.e., advertising that is integrated seamlessly into existing content) represent new frontiers for advertising and marketing commercial tobacco products and pose serious challenges for tobacco prevention and control. Because these tactics allow for more focused and segmented targeting, they have the potential to exacerbate existing disparities in initiation and use of specific products. Efforts to monitor and counter these tactics require innovative methods and dedicated resources.

A growing body of evidence suggests that middle and high school students’ exposure to e-cigarette advertising and promotional efforts via social media platforms is associated with e-cigarette initiation and daily use among those in this population. The evidence from the studies reviewed in this chapter further demonstrates disparities by race and ethnicity, SES, and sexual orientation and gender identity in receipt and use of coupons or discounts on tobacco products. The wide array of media platforms (e.g., social media, online, television, etc.) enables the tobacco industry to continue to utilize targeted marketing and advertising of tobacco products to adolescents and adults.

Finally, the tobacco industry continues to employ political, legal, economic, public relations, and community tactics that undermine tobacco prevention and control efforts. The evidence shows that tobacco companies seek to improve how they are perceived in minoritized racial and ethnic communities by funding and donating to various political groups and nonprofit organizations and by sponsoring organizations and events. Through these tactics, the industry promotes normalization of tobacco use and brand loyalty and builds opposition to health-protective tobacco control policies (Yerger and Malone 2002; Portugal et al. 2004; Offen et al. 2008; Wailoo 2021; Yerger 2022). The industry also utilizes economic tactics, such as price discounts and coupons, to minimize the impact of tax increases on profits and consumption. These tactics have the potential to hinder tobacco prevention and control efforts aimed at advancing health equity.

## Conclusions

1. Tobacco marketing in general and marketing for menthol cigarettes in particular are more prevalent in neighborhoods with greater percentages of African American residents or of residents with lower incomes compared with neighborhoods with lower percentages of African American residents or of residents with higher incomes.
2. Communities with high concentrations of people from diverse racial and ethnic population groups, residents with lower income, and adolescents tend to have greater availability of cheaper tobacco products, including menthol cigarettes, that are widely available at local retailers.
3. Members of the LGBTQI+ community and people with lower socioeconomic status are more likely to receive and use a coupon or price discount code to purchase tobacco products compared with their heterosexual and cisgender counterparts and those of higher socioeconomic status. Use of coupons appears to increase the likelihood of tobacco initiation among people who have never used tobacco and to reduce the likelihood of quitting among people who use tobacco.
4. Seismic shifts in the media environment have produced rapid changes in marketing strategies for commercial tobacco. Tactics such as influencer marketing that allow more focused and segmented targeting have the potential to exacerbate existing disparities in tobacco initiation and use.
5. The tobacco industry continues to employ political, legal, economic, corporate social responsibility, and community tactics to enhance its image among the communities it targets in marketing—including minoritized racial and ethnic groups and sexual orientation and gender identity groups that are subject to tobacco-related health disparities—and/or to counter efforts that would benefit public health and advance health equity.

## References

Action on Smoking & Health. United States of America: Tobacco Industry Interference Index 2021, 2021; <https://ash.org/wp-content/uploads/2021/11/USTIII_ASH_2021_Final.pdf>; accessed: July 28, 2023.
Agaku IT, Ayo-Yusuf OA. The effect of exposure to protobacco advertising on experimentation with emerging tobacco products among U.S. adolescents. Health Education & Behavior 2014;41(3):275–80.24347143
Agaku IT, Davis K, Patel D, Shafer P, Cox S, Ridgeway W, King BA. A longitudinal study of the relationship between receptivity to e-cigarette advertisements and e-cigarette use among baseline non-users of cigarettes and e-cigarettes, United States. Tobacco Induced Diseases 2017;15:42.29142532
Agaku IT, King BA, Dube SR. Trends in exposure to protobacco advertisements over the Internet, in newspapers/magazines, and at retail stores among U.S. middle and high school students, 2000–2012. Preventive Medicine 2014;58:45–52.24183778
Agenbroad A, Rojas J, Chatila B M-A. Request for title and summary for proposed referendum [letter to Honorable Xavier Becerra], August 31, 2020; <https://oag.ca.gov/system/files/initiatives/pdfs/20-0003%20%28Tobacco%20Products%20%29.pdf>; accessed: July 28, 2023.
Ajzen I, Fishbein M. Understanding Attitudes and Predicting Social Behaviour. Englewood Cliffs (NJ): Prentice-Hall, 1980.
Albarracin D, Johnson BT, Zanna MP. The Handbook of Attitudes. New York (NY): Psychology Press, 2014.
Ali FRM, Dave DM, Colman GJ, Wang X, Saffer H, Marynak KL, Dench D, Grossman M. Association of e-cigarette advertising with e-cigarette and cigarette use among U.S. adults. Addiction 2021;116(5):1212–23.33271632
Ali FRM, Diaz MC, Vallone D, Tynan MA, Cordova J, Seaman EL, Trivers KF, Schillo BA, Talley B, King BA. E-cigarette unit sales, by product and flavor type—United States, 2014–2020. Morbidity and Mortality Weekly Report 2020;69(37):1313–8.32941416
Ali FRM, Seaman EL, Schillo B, Vallone D. Trends in annual sales and pack price of cigarettes in the U.S., 2015–2021. JAMA Network Open 2022;5(6):e2215407.35657628
All Ways Advertising. Hawaii Research 851113-851119. November 13, 1985. Lorillard Records Collection. Bates No. 87024726-87024730. <https://www.industrydocuments.ucsf.edu/docs/#id=jyjj0077>.
Allem JP, Dharmapuri L, Unger JB, Cruz TB. Characterizing JUUL-related posts on Twitter. Drug and Alcohol Dependence 2018;190:1–5.29958115
Allem JP, Escobedo P, Chu KH, Soto DW, Cruz TB, Unger JB. Campaigns and counter campaigns: reactions on Twitter to e-cigarette education. Tobacco Control 2017a;26(2):226–9.26956467
Allem JP, Ramanujam J, Lerman K, Chu KH, Boley Cruz T, Unger JB. Identifying sentiment of hookah-related posts on Twitter. JMIR Public Health and Surveillance 2017b;3(4):e74.29046267
Altria. 2022 recipients of charitable contributions from the Altria family of companies, 2022; <https://www.altria.com/-/media/Project/Altria/Altria/people-and-careers/our-people-and-communities/community-engagement-and-partnership/grantees-list-for-altriacom.pdf>; accessed: July 28, 2023.
Altria. 2017 recipients of charitable contributions from the Altria family of companies, n.d.a; <https://www.documentcloud.org/documents/21088888-2017-recipients-of-charitable-contributions-from-the-altria-family-of-companies>; accessed: February 11, 2019.
Altria. 2021 recipients of charitable contributions from the Altria family of companies, n.d.b; <https://www.altria.com/-/media/Project/Altria/Altria/people-and-careers/our-people-and-communities/community-engagement-and-partnership/grantees-list-for-altriacom.pdf>; accessed: November 4, 2022.
Altria. Altria’s race & equity initiative, n.d.c; <https://www.altria.com/people-and-careers/our-people-and-communities/inclusion-diversity-and-equity>; accessed: November 10, 2022.
American Lung Association. Big Tobacco’s Next Frontier: Sustaining Addiction & Hooking Kids with Other Tobacco Products, n.d.; <https://www.lung.org/getmedia/28ccaf29-2395-4515-8cb9-7b88e19859b9/big-tobaccos-next-frontier.pdf.pdf>; accessed: February 11, 2019.
Anderson M, Jiang J. Teens, Social Media & Technology 2018. Washington (DC): Pew Research Center, 2018.
Apollonio DE, Bero LA. The creation of industry front groups: the tobacco industry and “get government off our back”. American Journal of Public Health 2007;97(3):419–27.17267719
Apollonio DE, Malone RE. Marketing to the marginalised: tobacco industry targeting of the homeless and mentally ill. Tobacco Control 2005;14(6):409–15.16319365
Apollonio DE, Malone RE. The “We Card” program: tobacco industry “youth smoking prevention” as industry self-preservation. American Journal of Public Health 2010;100(7):1188–201.20466965
Assari S. Association of educational attainment and race/ethnicity with exposure to tobacco advertisement among U.S. young adults. JAMA Network Open 2020;3(1):e1919393.31951271
Auxier B, Anderson M. Social Media Use in 2021, 2021; <https://www.pewresearch.org/internet/wp-content/uploads/sites/9/2021/04/PI_2021.04.07_Social-Media-Use_FINAL.pdf>; accessed: February 9, 2023.
Bandura A. Social Foundation of Thought and Action: A Social Cognitive Theory. Englewood Cliffs (NJ): Prentice Hall, 1986.
Banerjee S, Shuk E, Greene K, Ostroff J. Content analysis of trends in print magazine tobacco advertisements. Tobacco Regulatory Science 2015;1(2):103–20.26236763
Barbeau EM, Wolin KY, Naumova EN, Balbach E. Tobacco advertising in communities: associations with race and class. Preventive Medicine 2005;40(1):16–22.15530576
Barker JO, Rohde JA. Topic clustering of e-cigarette submissions among Reddit communities: a network perspective. Health Education and Behavior 2019;46(Suppl 2):59–68.31742448
Basch CH, Mongiovi J, Hillyer GC, Ethan D, Hammond R. An analysis of electronic cigarette and cigarette advertising in U.S. women’s magazines. International Journal of Preventive Medicine 2016;7:103.27688867
Batra R, Ray ML. Affective responses mediating acceptance of advertising. Journal of Consumer Research 1986;13(2):234–49.
Bernat DH, Choi K. Differences in cigarette use and the tobacco environment among youth living in metropolitan and nonmetropolitan areas. Journal of Rural Health 2018;34(1):80–7.
Bero L. Implications of the tobacco industry documents for public health and policy. Annual Review of Public Health 2003;24:267–88.
Bessi A, Zollo F, Del Vicario M, Scala A, Caldarelli G, Quattrociocchi W. Trend of narratives in the age of misinformation. PLoS One 2015;10(8):e0134641.26275043
Big Time Vapes, Inc. v. FDA, 963 F.3d 436 (5th Cir. 2020).
Booker B. TV Broadcasters to stop taking e-cigarette ads, September 19, 2019; <https://www.npr.org/sections/health-shots/2019/09/19/762410165/tv-broadcasters-to-stop-taking-e-cigarette-ads>; accessed: May 23, 2022.
Bostean G, Sanchez L, Lippert AM. Sociodemographic disparities in e-cigarette retail environment: vape stores and census tract characteristics in Orange County, CA. Health & Place 2018;50:65–72.29414423
Bostean G, Sánchez LA, Douglas JA. Spatial disparities: the role of nativity in neighborhood exposure to alcohol and tobacco retailers. Journal of Immigrant and Minority Health 2022;24(4):945–55.34591231
Braak DC, Cummings KM, Nahhas GJ, Heckman BW, Borland R, Fong GT, Hammond D, Boudreau C, McNeill A, Levy DT, . Where do vapers buy their vaping supplies? Findings from the International Tobacco Control (ITC) 4 Country Smoking and Vaping Survey. International Journal of Environmental Research and Public Health 2019;16(3):338.30691091
Bradbury-Sullivan LGBT Community Center. LGBTQ+ tobacco-free, n.d.; <https://www.bradburysullivancenter.org/tobaccofree>; accessed: July 17, 2023.
Branstetter SA, Lengerich E, Dignan M, Muscat J. Knowledge and perceptions of tobacco-related media in rural Appalachia. Rural and Remote Health 2015;15:3136.25754624
Brock B, Choi K, Boyle RG, Moilanen M, Schillo BA. Tobacco product prices before and after a statewide tobacco tax increase. Tobacco Control 2016;25(2):166–73.25564283
Brown-Johnson CG, England LJ, Glantz SA, Ling PM. Tobacco industry marketing to low socioeconomic status women in the U.S.A. Tobacco Control 2014;23(e2):e139–e146.24449249
Brown D, Hayes N. Influencer Marketing: Who Really Influences Your Customers? Oxford (UK): Butterworth-Heinmann/Elsevier, 2008.
Brown EM, Rogers T, Eggers ME, Cavazos ML, O’Brien MS, McCrae T, Farley SM, Schroth KRJ. Implementation of the New York City policy restricting sales of flavored non-cigarette tobacco products. Health Education & Behavior 2019;46(5):782–9.31170825
Burgoon ML, Albani T, Keller-Hamilton B, Lu B, Roberts ME, Craigmile PF, Browning C, Xi W, Ferketich AK. Exposures to the tobacco retail environment among adolescent boys in urban and rural environments. American Journal of Drug and Alcohol Abuse 2019;45(2):217–26.30601033
Burson-Marstellar. PM21 DV Meeting II Core Messages/Channel Discussion, April 24, 2000: Summary of Meeting Notes. April 27, 2000. Philip Morris Records Collection. Bates No. 2081235882-2081235900. <https://www.industrydocuments.ucsf.edu/docs/hrvd0069>.
Camenga D, Gutierrez KM, Kong G, Cavallo D, Simon P, Krishnan-Sarin S. E-cigarette advertising exposure in e-cigarette naive adolescents and subsequent e-cigarette use: a longitudinal cohort study. Addictive Behaviors 2018;81:78–83.29432916
Campaign for Tobacco-Free Kids. Tobacco PAC contributions to federal candidates, 2020; <https://www.tobaccofreekids.org/what-we-do/us/tobacco-campaign-contributions>; accessed: July 28, 2023.
Campaign for Tobacco-Free Kids. Tobacco product marketing on the Internet, November 3, 2021; <https://www.tobaccofreekids.org/assets/factsheets/0081.pdf>; accessed: July 27, 2023.
Cantrell J, Anesetti-Rothermel A, Pearson JL, Xiao H, Vallone D, Kirchner TR. The impact of the tobacco retail outlet environment on adult cessation and differences by neighborhood poverty. Addiction 2015a;110(1):152–61.25171184
Cantrell J, Ganz O, Anesetti-Rothermel A, Harrell P, Kreslake JM, Xiao H, Pearson JL, Vallone D, Kirchner TR. Cigarette price variation around high schools: evidence from Washington DC. Health & Place 2015b;31:193–8.25560754
Cantrell J, Kreslake J, Ganz O, Pearson JL, Vallone DM, Anesetti-Rothermel A, Xiao H, Kirchner TR. Cantrell et al. respond. American Journal of Public Health 2014;104(4):e1–e2.
Cantrell J, Kreslake JM, Ganz O, Pearson JL, Vallone D, Anesetti-Rothermel A, Xiao H, Kirchner TR. Marketing little cigars and cigarillos: advertising, price, and associations with neighborhood demographics. American Journal of Public Health 2013;103(10):1902–9.23948008
Cappella JN, Kim HS, Albarracin D. Selection and transmission processes for information in the emerging media environment: psychological motives and message characteristics. Media Psychology 2015;18(3):396–424.26190944
Carroll DM, Soto C, Baezconde-Garbanati L, Huang LL, Lienemann BA, Meissner HI, Rose SW, Unger JB, Cruz TB. Tobacco industry marketing exposure and commercial tobacco product use disparities among American Indians and Alaska Natives. Substance Use & Misuse 2020;55(2):261–70.31544562
Carter D. Hustle and brand: the sociotechnical shaping of influence. Social Media + Society 2016;2(3):1–12.
Center for Public Health Systems Science. Point-of-Sale Report to the Nation: The Tobacco Retail and Policy Landscape. St. Louis (MO): Center for Public Health Systems Science at the Brown School at Washington University in St. Louis and the National Cancer Institute, State and Community Tobacco Control Research Initiative, 2014.
Centers for Disease Control and Prevention. Notes from the field: electronic cigarette use among middle and high school students—United States, 2011–2012. Morbidity and Mortality Weekly Report 2013;62(35):729–30.24005229
Centers for Disease Control and Prevention. E-cigarette ads and youth, January 2016; <https://www.cdc.gov/vitalsigns/pdf/2016-01-vitalsigns.pdf>; accessed: November 20, 2023.
Centers for Disease Control and Prevention. Legislation, n.d.a; <https://www.cdc.gov/tobacco/basic_information/policy/legislation/index.htm>; accessed: November 13, 2023.
Centers for Disease Control and Prevention. STATE System licensure fact sheet, n.d.b; <https://www.cdc.gov/statesystem/factsheets/licensure/Licensure.html>; accessed: November 4, 2022.
Chaiton MO, Mecredy G, Cohen J. Tobacco retail availability and risk of relapse among smokers who make a quit attempt: a population-based cohort study. Tobacco Control 2018;27(2):163–9.28432213
Chaloupka FJ, Straif K, Leon ME. Effectiveness of tax and price policies in tobacco control. Tobacco Control 2011;20(3):235–8.21115556
Chang J. Can’t Stop Won’t Stop: A History of the Hip-Hop Generation. New York (NY): St. Martin’s Press, 2005.
Chen-Sankey J, Unger JB, Bernat E, Niederdeppe J, Bansal-Travers M, Choi K. Price promotion receipt and use progression of any tobacco, cigarettes, e-cigarettes and cigars among U.S. youth between 2016 and 2018. Tobacco Control 2023;32(2):225–32.34301838
Chen-Sankey JC, Unger JB, Bansal-Travers M, Niederdeppe J, Bernat E, Choi K. E-cigarette marketing exposure and subsequent experimentation among youth and young adults. Pediatrics 2019;144(5):e20191119.31659003
Chew R, Kery C, Baum L, Bukowski T, Kim A, Navarro M. Predicting age groups of Reddit users based on posting behavior and metadata: classification model development and validation. JMIR Public Health and Surveillance 2021;7(3):e25807.33724195
Chew R, Wenger M, Guillory J, Nonnemaker J, Kim A. Identifying electronic nicotine delivery system brands and flavors on Instagram: natural language processing analysis. Journal of Medical Internet Research 2022;24(1):e30257.35040793
Cheyne A, Dorfman L, Daynard RA, Mejia P, Gottlieb M. The debate on regulating menthol cigarettes: closing a dangerous loophole vs freedom of choice. American Journal of Public Health 2014;104(7):e54–e61.
Chido-Amajuoyi OG, Ozigbu CE, Zhang K. School proximity and census tract correlates of e-cigarette specialty retail outlets (vape shops) in central Texas. Preventive Medicine Reports 2020;18:101079.32257777
Choi K, Forster JL. Frequency and characteristics associated with exposure to tobacco direct mail marketing and its prospective effect on smoking behaviors among young adults from the U.S. Midwest. American Journal of Public Health 2014;104(11):2179–83.25211739
Choi K, Rose SW, Zhou Y, Rahman B, Hair E. Exposure to multimedia tobacco marketing and product use among youth: a longitudinal analysis. Nicotine & Tobacco Research 2020;22(6):1036–40.31198962
Choi WS, Gilpin EA, Farkas AJ, Pierce JP. Determining the probability of future smoking among adolescents. Addiction 2001;96(2):313–23.11182877
Chu KH, Matheny SJ, Sidani JE, Allem JP, Unger JB, Cruz TB. Instagram’s #JUUL: who’s posting what. Translational Behavioral Medicine 2021;11(1):257–61.31912873
Chuang YC, Cubbin C, Ahn D, Winkleby MA. Effects of neighbourhood socioeconomic status and convenience store concentration on individual level smoking. Journal of Epidemiology and Community Health 2005;59(7):568–73.15965140
Cigar Association of America v. U.S. Food & Drug Administration, 964 F.3d 56 (D.C. Cir. 2020).
City of Providence. Section 14-309. Sale of flavored tobacco products prohibited. In: Chapter 2012-6. No. 42. An Ordinance Amending Article XV of Chapter 14 of the Code of Ordinances of the City of Providence, Entitled: “Licenses” by Adding Thereto the Following Sections, January 9, 2012; <https://providenceri.gov/wp-content/uploads/2017/05/Flavored-Tobacco-Ordinance-2012-6.42.pdf>; accessed: July 17, 2023.
Clarke T. Appeals court upholds FDA’s right to use menthol cigarettes report, January 15, 2016; <https://www.reuters.com/article/us-tobacco-fda-court-idUSKCN0UT25L?feedType=RSS&feedName=healthNews>; accessed: February 11, 2019.
Clendennen SL, Loukas A, Vandewater EA, Perry CL, Wilkinson AV. Exposure and engagement with tobacco-related social media and associations with subsequent tobacco use among young adults: a longitudinal analysis. Drug and Alcohol Dependence 2020;213:108072.32563115
Cohen J, Gilmore A, Legg T, Laurence L, Eissenburg T, Czaplicki L, Hoe C. The Foundation for a Smoke-Free World—even less independent from its tobacco company funder [blog post], August 10, 2021; <https://blogs.bmj.com/bmj/2021/08/10/the-foundation-for-a-smoke-free-world-even-less-independent-from-its-tobacco-company-funder>; accessed: May 24, 2021.
Cohn AM, Rose SW, Ilakkuvan V, Gray T, Curry L, Villanti AC, Mays D, Lindblom E, Tercyak K, Debnam C, . Harm perceptions of menthol and nonmenthol cigarettes differ by brand, race/ethnicity, and gender in U.S. adult smokers: results from PATH wave 1. Nicotine & Tobacco Research 2019;21(4):439–49.29385527
Collins L, Glasser AM, Abudayyeh H, Pearson JL, Villanti AC. E-cigarette marketing and communication: how e-cigarette companies market e-cigarettes and the public engages with e-cigarette information. Nicotine & Tobacco Research 2019;21(1):14–24.29315420
Comprehensive Smokeless Tobacco Health Education Act of 1986, Public Law 99–252, 100 Stat 30 (1986), codified at 15 U.S. Code § 4402(f).
Congressional Black Caucus Health Braintrust. Rep. Kelly leads letter in support of menthol cigarette ban [press release], August 1 2023a; <https://robinkelly.house.gov/media-center/press-releases/rep-kelly-leads-letter-support-menthol-cigarette-ban>; accessed: September 5, 2023.
Congressional Black Caucus Health Braintrust. Rep. Kelly leads majority of CBC members in letter to FDA in support of proposed menthol cigarette ban [press release], July 20, 2023b; <https://robinkelly.house.gov/media-center/press-releases/rep-kelly-leads-majority-cbc-members-letter-fda-support-proposed>; accessed: September 5, 2023.
Consolidated Appropriations Act of 2022. Public Law 117–103, U.S. Statutes at Large 136 (2022):49.
Coreas SI, Rodriquez EJ, Rahman SG, El-Toukhy S, Compton WM, Blanco C, Kimmel HL, Perez-Stable EJ. Smoking susceptibility and tobacco media engagement among youth never smokers. Pediatrics 2021;147(6):e2020017921.33941582
Cortese DK, Szczypka G, Emery S, Wang S, Hair E, Vallone D. Smoking selfies: using Instagram to explore young women’s smoking behaviors. Social Media + Society 2018;4(3):2056305118790762.
Countertobacco.org. Double your student discount [store promotional signage], 2022a; <https://countertobacco.org/wp-content/gallery/main-galleru/Student-Discount-Bring-A-Friend.jpeg>; accessed: November 10, 2022.
Countertobacco.org. Tobacco Depot fine cigars [pole signage outside a retail store], 2022b; <https://countertobacco.org/wp-content/gallery/main-galleru/PXL_20221020_114249452.jpeg>; accessed: November 10, 2022.
Countertobacco.org. Welcome to Seneca country [exterior promotional banner], n.d.; <https://countertobacco.org/wp-content/gallery/main-galleru/Seneca-Country-2.jpg>; accessed: November 10, 2022.
Cranwell J, Murray R, Lewis S, Leonardi-Bee J, Dockrell M, Britton J. Adolescents’ exposure to tobacco and alcohol content in YouTube music videos. Addiction 2015;110(4):703–11.25516167
Crellin R. Organic Tobacco. [letter to Elui Krugel, British American Tobacco]. August 29, 2000. British American Tobacco Records Collection. Bates No. 325407353-325407357. <https://www.industrydocuments.ucsf.edu/docs/thnm0197>.
Cruz TB. Monitoring the tobacco use epidemic IV. The vector: tobacco industry data sources and recommendations for research and evaluation. Preventive Medicine 2009;48(1 Suppl):S24–S34.18976685
Cruz TB, McConnell R, Low BW, Unger JB, Pentz MA, Urman R, Berhane K, Chou CP, Liu F, Barrington-Trimis JL. Tobacco marketing and subsequent use of cigarettes, e-cigarettes, and hookah in adolescents. Nicotine & Tobacco Research 2019a;21(7):926–32.29846704
Cruz TB, Rose SW, Lienemann BA, Byron MJ, Meissner HI, Baezconde-Garbanati L, Huang LL, Carroll DM, Soto C, Unger JB. Pro-tobacco marketing and anti-tobacco campaigns aimed at vulnerable populations: a review of the literature. Tobacco Induced Diseases 2019b;17:68.31582956
Cruz TB, Wright LT, Crawford G. The menthol marketing mix: targeted promotions for focus communities in the United States. Nicotine & Tobacco Research 2010;12(Suppl 2):S147–S153.21177371
Curfman G. Graphic cigarette warning labels, the first amendment, and public right to accurate public health information: graphic cigarette warning labels back under legal scrutiny. JAMA Health Forum 2021;2(9):e212886.36218662
Czaplicki L, Kostygina G, Kim Y, Perks SN, Szczypka G, Emery SL, Vallone D, Hair EC. Characterising JUUL-related posts on Instagram. Tobacco Control 2019;29(6):612–7.31266903
D’Angelo H, Ammerman A, Gordon-Larsen P, Linnan L, Lytle L, Ribisl KM. Sociodemographic disparities in proximity of schools to tobacco outlets and fast-food restaurants. American Journal of Public Health 2016;106(9):1556–62.27459453
D’Angelo H, Ayala GX, Gittelsohn J, Laska MN, Sindberg LS, Horton L, Kharmats AY, Ribisl KM. An analysis of small retailers’ relationships with tobacco companies in 4 U.S. cities. Tobacco Regulatory Science 2020a;6(1):3–14.
D’Angelo H, Rose SW, Golden SD, Queen T, Ribisl KM. E-cigarette availability, price promotions and marketing at the point-of sale in the contiguous United States (2014–2015): national estimates and multilevel correlates. Preventive Medicine Reports 2020b;19:101152.32670780
D’Silva J, O’Gara E, Villaluz NT. Tobacco industry misappropriation of American Indian culture and traditional tobacco. Tobacco Control 2018;27(e1):e57–e64.29459389
Dai H, Hao J. Exposure to advertisements and susceptibility to electronic cigarette use among youth. Journal of Adolescent Health 2016;59(6):620–6.
Dai H, Hao J. Geographic density and proximity of vape shops to colleges in the USA. Tobacco Control 2017;26(4):379–85.27302700
Dai H, Hao J, Catley D. Vape shop density and sociodemographic disparities: A U.S. Census Tract Analysis. Nicotine & Tobacco Research 2017;19(11):1338–44.28371830
Dal Cin S, Stoolmiller M, Sargent JD. Exposure to smoking in movies and smoking initiation among black youth. American Journal of Preventive Medicine 2013;44(4):345–50.23498099
Dauphinee AL, Doxey JR, Schleicher NC, Fortmann SP, Henriksen L. Racial differences in cigarette brand recognition and impact on youth smoking. BMC Public Health 2013;13(1):170.23442215
Dave D, Saffer H. Demand for smokeless tobacco: Role of advertising. Journal of Health Economics 2013;32(4):682–97.23660106
Delnevo CD, Giovenco DP, Miller Lo EJ. Changes in the mass-merchandise cigar market since the Tobacco Control Act. Tobacco Regulatory Science 2017; 3(2 Suppl 1):S8–S16.28317004
Department of the Navy, Office of the Secretary. SECNAV Instruction 5100.13F, December 2, 2020; <https://www.secnav.navy.mil/doni/Directives/05000%20General%20Management%20Security%20and%20Safety%20Services/05-100%20Safety%20and%20Occupational%20Health%20Services/5100.13F.pdf>; accessed: December 22, 2022.
Depue JB, Southwell BG, Betzner AE, Walsh BM. Encoded exposure to tobacco use in social media predicts subsequent smoking behavior. American Journal of Health Promotion 2015;29(4):259–61.24670071
DiFranza JR, Wellman RJ, Sargent JD, Weitzman M, Hipple BJ, Winickoff JP. Tobacco promotion and the initiation of tobacco use: assessing the evidence for causality. Pediatrics 2006;117(6):e1237.16740823
Dilley JA, Spigner C, Boysun MJ, Dent CW, Pizacani BA. Does tobacco industry marketing excessively impact lesbian, gay and bisexual communities? Tobacco Control 2008;17(6):385–90.18723561
Discount Tobacco City & Lottery, Inc. v. United States, 674 F.3d 509 (6th Cir. 2012).
Dooren JC. Lorillard, R.J. Reynolds sue FDA. The Wall Street Journal, 2011; <https://www.wsj.com/articles/SB10001424052748703409304576166881908728052>; accessed: February 12, 2019.
Dube SR, Arrazola RA, Lee J, Engstrom M, Malarcher A. Pro-tobacco influences and susceptibility to smoking cigarettes among middle and high school students—United States, 2011. Journal of Adolescent Health 2013;52(5 Suppl):S45–S51.
Duke JC, Lee YO, Kim AE, Watson KA, Arnold KY, Nonnemaker JM, Porter L. Exposure to electronic cigarette television advertisements among youth and young adults. Pediatrics 2014;134(1):e29–e36.24918224
Duncan DT, Kawachi I, Melly SJ, Blossom J, Sorensen G, Williams DR. Demographic disparities in the tobacco retail environment in Boston: a citywide spatial analysis. Public Health Reports 2014;129(2):209–15.24587559
Dutch Masters. Black lives matter [Instagram post], 2020; <https://www.instagram.com/p/CA5WqHkg2Zu/>; accessed: November 10, 2022.
Dutta-Bergman MJ. Primary sources of health information: comparisons in the domain of health attitudes, health cognitions, and health behaviors. Health Communication 2004;16(3):273–88.15265751
Elhabashy M, Wackowski OA, Mercincavage M, Cruz-Cano R, Abadi MH, Ozga JE, Stanton CA, Chen-Sankey J. Longitudinal associations between receiving e-cigarette price promotions and subsequent e-cigarette use among U.S. young adult cigarette smokers. Addictive Behaviors 2023;138:107549.36410256
Emery S, Kim Y, Choi YK, Szczypka G, Wakefield M, Chaloupka FJ. The effects of smoking-related television advertising on smoking and intentions to quit among adults in the United States: 1999–2007. American Journal of Public Health 2012;102(4):751–7.22397350
Emery SL, Vera L, Huang J, Szczypka G. Wanna know about vaping? Patterns of message exposure, seeking and sharing information about e-cigarettes across media platforms. Tobacco Control 2014;23(Suppl 3): iii17–iii25.24935893
Emory K, Buchting FO, Trinidad DR, Vera L, Emery SL. Lesbian, gay, bisexual and transgender (LGBT) view it differently than non-LGBT: exposure to tobacco-related couponing, e-cigarette advertisements, and anti-tobacco messages on social and traditional media. Nicotine & Tobacco Research 2019;21(4):513–22.29546337
Epperson AE, Johnson TO, Schleicher NC, Henriksen L. The price of Natural American Spirit relative to other cigarette brands. Nicotine & Tobacco Research 2019;21(12):1715–20.30759248
Ernster VL. Advertising and promotion of smokeless tobacco products. NCI Monographs 1989;(8):87–94.2654652
Escobedo P, Garcia R, Soto C, Rodriguez Y, Barahona R, Baezconde-Garbanati L. Comparison of e-cigarette marketing and availability in tobacco retail outlets among diverse low-income communities in California. Tobacco Control 2020a;29:469–71.31324661
Escobedo P, Tsai KY, Majmundar A, Allem JP, Soto DW, Pattarroyo M, Unger JB, Cruz TB. Do tobacco industry websites target content to specific demographic groups? Drug and Alcohol Dependence 2020b;208:107852.31991328
Evans WN, Ringel JS, Stech D. Tobacco taxes and public policy to discourage smoking. Tax Policy and the Economy 1999;13:1–55.
Fakunle D, Morton CM, Peterson NA. The importance of income in the link between tobacco outlet density and demographics at the tract level of analysis in New Jersey. Journal of Ethnicity in Substance Abuse 2010;9(4):249–59.21161808
Fakunle DO, Curriero FC, Leaf PJ, Furr-Holden DM, Thorpe RJ. Black, white, or green? The effects of racial composition and socioeconomic status on neighborhood-level tobacco outlet density. Ethnicity & Health 2019a:1–16.
Fakunle DO, Eck R, Milam AJ, Thorpe RJ, Jr., Furr-Holden DM. E-cigarettes in Baltimore alcohol outlets: geographic and demographic correlates of availability. Family & Community Health 2018;41(4):205–13.30134335
Fakunle DO, Milam AJ, Furr-Holden CD, Butler J 3rd, Thorpe RJ Jr, LaVeist TA. The inequitable distribution of tobacco outlet density: the role of income in two Black mid-Atlantic geopolitical areas. Public Health 2016;136:35–40.27076440
Fakunle DO, Thorpe RJ Jr, Furr-Holden CDM, Curriero FC, Leaf PJ. Does tobacco outlet inequality extend to high-white mid-Atlantic jurisdictions? A study of socioeconomic status and density. Journal of Racial and Ethnic Health Disparities 2019b;6(2):409–18.30446987
Fallin A, Davis B. LGBT organisation successfully advocated for ban on tobacco promotions in San Jose, California. Tobacco Control 2016;25(5):504–5.26758029
Family Smoking Prevention and Tobacco Control Act, Public Law 111–31, 123 U.S. Statutes at Large 1776 (2009a).
Farley SM, Sisti J, Jasek J, Schroth KRJ. Flavored tobacco sales prohibition (2009) and noncigarette tobacco products in retail stores (2017), New York City. American Journal of Public Health 2020;110(5):725–30.32191512
Farrelly MC. Monitoring the tobacco use epidemic V: the environment: factors that influence tobacco use. Preventive Medicine 2009;48(1 Suppl):S35–S43.19022281
Farrelly MC, Bray JW, Pechacek T, Woollery T. Response by adults to increases in cigarette prices by sociodemographic characteristics. Southern Economic Journal 2001;68(1):156–65.
Farrelly MC, Duke JC, Crankshaw EC, Eggers ME, Lee YO, Nonnemaker JM, Kim AE, Porter L. A Randomized Trial of the Effect of E-cigarette TV Advertisements on Intentions to Use E-cigarettes. American Journal of Preventive Medicine 2015;49(5):686–93.26163170
Federal Deposit Insurance Corporation. 2021 FDIC national survey of unbanked and underbanked households, November 14, 2022; <https://www.fdic.gov/analysis/household-survey/index.html>; accessed: December 21, 2022.
Federal Register. U.S. Department of Health and Human Services, U.S. Food and Drug Administration. Regulations restricting the sale and distribution of cigarettes and smokeless tobacco to protect children and adolescents, final rule (21 CFR 1140), 75 Fed. Reg. 13225 (2010).
Federal Register. U.S. Department of Health and Human Services, Food and Drug Administration. Deeming tobacco products to be subject to the Federal Food, Drug, and Cosmetic Act, as amended by the Family Smoking Prevention and Tobacco Control Act; restrictions on the sale and distribution of tobacco products and required warning statements for tobacco products, 81 Fed. Reg. 28973 (2016); <https://www.federalregister.gov/d/2016-10685>; accessed: February 19, 2019.
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Tobacco product standard for menthol in cigarettes (proposed product standard) (21 CFR 1162), 87 Fed. Reg. 26454 (2022a).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Tobacco Product Standard for Characterizing Flavors in Cigars (proposed product standard) (21 CFR 1166), 87 Fed. Reg. 26396 (2022b).
Federal Trade Commission. Federal Trade Commission Cigarette Report for 2019. Washington (DC): U.S. Department of Commerce, 2021a.
Federal Trade Commission. Federal Trade Commission Cigarette Report for 2020 and Smokeless Tobacco Report for 2020. Washington (DC): U.S. Department of Commerce, 2021b.
Federal Trade Commission. Federal Trade Commission E-Cigarette Report for 2019–2020. Washington (DC): U.S. Department of Commerce, 2022.
Feighery EC, Ribisl KM, Clark PI, Haladjian HH. How tobacco companies ensure prime placement of their advertising and products in stores: interviews with retailers about tobacco company incentive programmes. Tobacco Control 2003;12(2):184.12773729
Feighery EC, Schleicher NC, Boley Cruz T, Unger JB. An examination of trends in amount and type of cigarette advertising and sales promotions in California stores, 2002–2005. Tobacco Control 2008;17(2):93–8.18303088
Fishbein M, Ajzen I. Belief, Attitude, Intention, and Behavior: An Introduction to Theory and Research. Reading (MA): Addison-Wesley, 1975.
Fooks G, Gilmore A, Collin J, Holden C, Lee K. The limits of corporate social responsibility: techniques of neutralization, stakeholder management and political CSR. Journal of Business Ethics 2013;112(2):283–99.
Freeman B. New media and tobacco control. Tobacco Control 2012;21(2):139–44.22345236
Frick RG, Klein EG, Ferketich AK, Wewers ME. Tobacco advertising and sales practices in licensed retail outlets after the Food and Drug Administration regulations. Journal of Community Health 2012;37(5):963–7.22197961
Galiatsatos P, Kineza C, Hwang S, Pietri J, Brigham E, Putcha N, Rand CS, McCormack M, Hansel NN. Neighbourhood characteristics and health outcomes: evaluating the association between socioeconomic status, tobacco store density and health outcomes in Baltimore City. Tobacco Control 2018;27(e1):e19–e24.29170167
Ganz O, Rose SW, Cantrell J. Swisher Sweets “Artist Project”: using musical events to promote cigars. Tobacco Control 2018;27:e93–e95.29439208
Garcia-Cazarin ML, Mandal RJ, Grana R, Wanke KL, Meissner HI. Host-agent-vector-environment measures for electronic cigarette research used in NIH grants. Tobacco Control 2020;(Suppl 1):S43–S49.29332004
Garcia R, Sidhu A, Allem J, Baezconde-Garbanati L, Unger J, Sussman S. Marketing activities of vape shops across racial/ethnic communities. Tobacco Prevention & Cessation 2017;2(Supplement):12.
Gardiner PS. The African Americanization of menthol cigarette use in the United States. Nicotine & Tobacco Research 2004;6(Suppl 1):S55–S65.14982709
Gentzke AS, Wang TW, Cornelius M, Park-Lee E, Ren C, Sawdey MD, Cullen KA, Loretan C, Jamal A, Homa DM. Tobacco product use and associated factors among middle and high school students—National Youth Tobacco Survey, United States, 2021. Morbidity and Mortality Weekly Report Surveillance Summaries 2022;71(5):1–29.
Geyser W. The State of Influencer Marketing 2023: Benchmark Report, February 7, 2023; <https://influencermarketinghub.com/influencer-marketing-benchmark-report/>; accessed: July 17, 2023.
Giovenco DP. Smoke shop misclassification may cloud studies on vape shop density. Nicotine & Tobacco Research 2018;20(8):1025–6.28605478
Giovenco DP, Ackerman C, Hrywna M, Delnevo CD. Changes in the availability and promotion of non-cigarette tobacco products near high schools in New Jersey, USA. Tobacco Control 2018;27(5):578–9.28798262
Giovenco DP, Duncan DT, Coups EJ, Lewis MJ, Delnevo CD. Census tract correlates of vape shop locations in New Jersey. Health & Place 2016;40:123–8.27261635
Giovenco DP, Spillane TE, Mauro CM, Hernandez D. Evaluating the impact and equity of a tobacco-free pharmacy law on retailer density in New York City neighbourhoods. Tobacco Control 2019a;28(5):548–54.30135112
Giovenco DP, Spillane TE, Merizier JM. Neighborhood differences in alternative tobacco product availability and advertising in New York City: implications for health disparities. Nicotine & Tobacco Research 2019b;21(7):896–902.30452712
Giovino GA, Biener L, Hartman AM, Marcus SE, Schooley MW, Pechacek TF, Vallone D. Monitoring the tobacco use epidemic I. Overview: optimizing measurement to facilitate change. Preventive Medicine 2009;48(1 Suppl):S4–S10.18809429
Givel MS, Glantz SA. Tobacco lobby political influence on U.S. state legislatures in the 1990s. Tobacco Control 2001;10(2):124–34.11387532
Glasser AM, Johnson AL, Rath JM, Williams VF, Vallone DM, Villanti AC. Tobacco product brand preference among U.S. young adults, 2011–2014. Tobacco Regulatory Science 2016;2(1):44–55.
Glasser AM, Onnen N, Craigmile PF, Schwartz E, Roberts ME. Associations between disparities in tobacco retailer density and disparities in tobacco use. Preventive Medicine 2022;154:106910.34921833
Golden SD, Farrelly MC, Luke DA, Ribisl KM. Comparing projected impacts of cigarette floor price and excise tax policies on socioeconomic disparities in smoking. Tobacco Control 2016;25(Suppl 1):i60–i66.27697949
Golden SD, Kuo T-M, Kong AY, Baggett CD, Henriksen L, Ribisl KM. County-level associations between tobacco retailer density and smoking prevalence in the U.S.A., 2012. Preventive Medicine Reports 2019;17:101005.31934535
Grana RA, Ling PM. “Smoking revolution”: a content analysis of electronic cigarette retail websites. American Journal of Preventive Medicine 2014;46(4):395–403.24650842
Grilo G, Crespi E, Cohen JE. A scoping review on disparities in exposure to advertising for e-cigarettes and heated tobacco products and implications for advancing a health equity research agenda. International Journal of Equity in Health 2021;20(1):238.
Guttmann A. Media use in the U.S.—statistics and facts, January 19, 2023; <https://www.statista.com/topics/1536/media-use/>; accessed: February 10, 2023.
Haddock CK, Hoffman K, Taylor JE, Schwab L, Poston WS, Lando HA. An analysis of messages about tobacco in the Military Times magazines. Nicotine & Tobacco Research 2008;10(7):1191–7.18629729
Hafez N, Ling PM. Finding the Kool Mixx: how Brown & Williamson used music marketing to sell cigarettes. Tobacco Control 2006;15(5):359–66.16998169
Hall J, Cho HD, Maldonado-Molina M, George TJ Jr, Shenkman EA, Salloum RG. Rural-urban disparities in tobacco retail access in the southeastern United States: CVS vs. the dollar stores. Preventive Medicine Reports 2019;15:100935.31360628
Hamilton JL. The demand for cigarettes: advertising, the health scare, and the cigarette advertising ban. The Review of Economics and Statistics 1972;54(4):401.
Harakeh Z, Bogt T. The effect of rap/hip-hop music on young adult smoking: an experimental study. Substance Use & Misuse 2018;53(11):1819–25.29452016
Harris JK, Moreland-Russell S, Choucair B, Mansour R, Staub M, Simmons K. Tweeting for and against public health policy: response to the Chicago Department of Public Health’s electronic cigarette Twitter campaign. Journal of Medical Internet Research 2014;16(10):e238.25320863
Hawaii State Department of Health. Stronger together: we see community, big tobacco sees consumers, n.d.; <https://livinghealthy.hawaii.gov/stronger-together/>; accessed: July 17, 2023.
Healy M. Much heated puffing among minority groups over menthol. Los Angeles Times, October 18, 2010; <http://www.latimes.com/health/la-heb-menthol-101810-story.html>; accessed: February 12, 2019.
Hebert ET, Case KR, Kelder SH, Delk J, Perry CL, Harrell MB. Exposure and engagement with tobacco- and e-cigarette-related social media. Journal of Adolescent Health 2017;61(3):371–7.
Heley K, Popova L, Moran MB, Ben Taleb Z, Hart JL, Wackowski OA, Westling E, Smiley SL, Stanton CA. Targeted tobacco marketing in 2020: the case of #BlackLivesMatter. Tobacco Control 2023;32(4):530–3.34907090
Hendlin YH, Small S, Ling PM. ‘No-Barriers’ tobacco product? Selling smokeless tobacco to women, people of colour and the LGBTQ+ community in the USA. Tobacco Control 2023;32(3):330–7.34599083
Henriksen L, Andersen-Rodgers E, Zhang X, Roeseler A, Sun DL, Johnson TO, Schleicher NC. Neighborhood variation in the price of cheap tobacco products in California: results from healthy stores for a healthy community. Nicotine & Tobacco Research 2017;19(11):1330–7.28444233
Henriksen L, Feighery EC, Schleicher NC, Cowling DW, Kline RS, Fortmann SP. Is adolescent smoking related to the density and proximity of tobacco outlets and retail cigarette advertising near schools? Preventive Medicine 2008;47(2):210–4.18544462
Henriksen L, Feighery EC, Wang Y, Fortmann SP. Association of retail tobacco marketing with adolescent smoking. American Journal of Public Health 2004;94(12):2081–3.15569957
Henriksen L, Schleicher NC, Barker DC, Liu Y, Chaloupka FJ. Prices for tobacco and nontobacco products in pharmacies versus other stores: results from retail marketing surveillance in California and in the United States. American Journal of Public Health 2016;106(10):1858–64.27552272
Henriksen L, Schleicher NC, Dauphinee AL, Fortmann SP. Targeted advertising, promotion, and price for menthol cigarettes in California high school neighborhoods. Nicotine & Tobacco Research 2012;14(1):116–21.21705460
Henriksen L, Schleicher NC, Feighery EC, Fortmann SP. A longitudinal study of exposure to retail cigarette advertising and smoking initiation. Pediatrics 2010;126(2):232–8.20643725
Henriksen L, Schleicher NC, Johnson TO, Andersen-Rodgers E, Zhang X, Williams R. Mind the gap: changes in cigarette prices after California’s tax increase. Tobacco Regulatory Science 2019;5(6):532–41.32671140
Henriksen L, Schleicher NC, Johnson TO, Roeseler A, Zhu S-H. Retail tobacco marketing in rural versus nonrural counties: product availability, discounts, and prices. Health Promotion Practice 2020;21(1 Suppl): 27S–36S.31908200
Hillier A, Chilton M, Zhao QW, Szymkowiak D, Coffman R, Mallya G. Concentration of tobacco advertisements at SNAP and WIC stores, Philadelphia, Pennsylvania, 2012. Preventing Chronic Disease 2015;12:E15.25654220
Hirschhorn N. Corporate social responsibility and the tobacco industry: hope or hype? Tobacco Control 2004;13(4):447–53.15564636
Hsu G, Sun JY, Zhu SH. Evolution of electronic cigarettes brands from 2013–2014 to 2016–2017: analysis of brand websites. Journal of Medical Internet Research 2018;20(3):e80.29530840
Hu TW, Sung HY, Keeler TE. Reducing cigarette consumption in California: tobacco taxes vs an anti-smoking media campaign. American Journal of Public Health 1995;85(9):1218–22.7661228
Huang J, Duan Z, Kwok J, Binns S, Vera LE, Kim Y, Szczypka G, Emery SL. Vaping versus JUULing: how the extraordinary growth and marketing of JUUL transformed the U.S. retail e-cigarette market. Tobacco Control 2019;28(2):146–151.29853561
Huang J, Kornfield R, Emery SL. 100 million views of electronic cigarette YouTube videos and counting: quantification, content evaluation, and engagement levels of videos. Journal of Medical Internet Research 2016;18(3):e67.26993213
Huang J, Kornfield R, Szczypka G, Emery SL. A cross-sectional examination of marketing of electronic cigarettes on Twitter. Tobacco Control 2014;23(Suppl 3): iii26–iii30.24935894
Hur J, Gupta M. Growing up in the web of social networking: adolescent development and social media. Adolescent Psychiatry 2013;3(3):233–44.
Hyland A, Ambrose BK, Conway KP, Borek N, Lambert E, Carusi C, Taylor K, Crosse S, Fong GT, Cummings KM, . Design and methods of the Population Assessment of Tobacco and Health (PATH) Study. Tobacco Control 2017;26(4):371–8.27507901
Iglesias-Rios L, Parascandola M. A historical review of R.J. Reynolds’ strategies for marketing tobacco to Hispanics in the United States. American Journal of Public Health 2013;103(5):e15–e27.
Ishikawa Y, Kondo N, Kawachi I, Viswanath K. Are socioeconomic disparities in health behavior mediated by differential media use? Test of the communication inequality theory. Patient Education and Counseling 2016;99(11):1803–7.27349600
James CV, Moonesinghe R, Wilson-Frederick SM, Hall JE, Penman-Aguilar A, Bouye K. Racial/ethnic health disparities among rural adults—United States, 2012–2015. Morbidity and Mortality Weekly Report Surveillance Summaries 2017;66(23):1–9.
Jannat-Khah DP, Dill LJ, Reynolds SA, Joseph MA. Stress, socializing, and other motivations for smoking among the lesbian, gay, bisexual, transgender, and queer community in New York City. American Journal of Health Promotion 2018;32(5):1178–86.28318307
Jeong M. Sharing tobacco and e-cigarette information: predicting its occurrence and valence among youth and young adults. Health Communication 2018;33(9):1114–23.28622008
Johnson JD. Cancer-Related Information Seeking. Cresskill (NJ): Hampton Press, 1997.
Jones JP, Perry EL Jr. Smoke and mirrors: the Chicago defender, tobacco sponsorship, and the health of the African American public sphere. Journalism History 2022;48(4):303–23.
Kahlor L, Dunwoody S, Griffin RJ. Attributions in explanations of risk estimates. Public Understanding of Social Science 2002;11(3):243–57.
Kaplan S. Big tobacco’s global reach on social media. New York Times, August 24, 2018; <https://www.nytimes.com/2018/08/24/health/tobacco-social-media-smoking.html>; accessed: June 9, 2021.
Kates FR, Salloum RG, Thrasher JF, Islam F, Fleischer NL, Maziak W. Geographic proximity of waterpipe smoking establishments to colleges in the U.S. American Journal of Preventive Medicine 2016;50(1):e9–e14.26346294
Keighley JM. Can you handle the truth—compelled commercial speech and the First Amendment. University of Pennsylvania Journal of Constitutional Law 2012;15(2):539–618.
Kempf DS, Smith RE. Consumer processing of product trial and the influence of prior advertising: a structural modeling approach. Journal of Marketing Research 1998;35(3):325.
Kephart L, Song G, Henley P, Ursprung WWS. The association between neighborhood racial composition and menthol cigarette pricing in Boston, MA. Health & Place 2019;58:102144.31202096
Ketonen V, Malik A. Characterizing vaping posts on Instagram by using unsupervised machine learning. International Journal of Medical Informatics 2020;141:104223.32623330
Kim A, Miano T, Chew R, Eggers M, Nonnemaker J. Classification of Twitter users who tweet about e-cigarettes. JMIR Public Health and Surveillance 2017;3(3):e63.28951381
Kim AE, Hopper T, Simpson S, Nonnemaker J, Lieberman AJ, Hansen H, Guillory J, Porter L. Using Twitter data to gain insights into e-cigarette marketing and locations of use: an infoveillance study. Journal of Medical Internet Research 2015;17(11):e251.26545927
Kim Y, Emery SL, Vera L, David B, Huang J. At the speed of Juul: measuring the Twitter conversation related to ENDS and Juul across space and time (2017–2018). Tobacco Control 2021;30(2):137–46.32198278
King JL, Wagoner KG, Suerken CK, Song EY, Reboussin BA, Spangler J, Walker S, Cornacchione Ross J, Wolfson M, Sutfin EL. Are waterpipe cafe, vape shop, and traditional tobacco retailer locations associated with community composition and young adult tobacco use in North Carolina and Virginia? Substance Use & Misuse 2020;55(14):2395–402.32969275
Kirchner TR, Cantrell J, Anesetti-Rothermel A, Ganz O, Vallone DM, Abrams DB. Geospatial exposure to point-of-sale tobacco: real-time craving and smoking-cessation outcomes. American Journal of Preventive Medicine 2013;45(4):379–85.24050412
Kirchner TR, Villanti AC, Cantrell J, Anesetti-Rothermel A, Ganz O, Conway KP, Vallone DM, Abrams DB. Tobacco retail outlet advertising practices and proximity to schools, parks and public housing affect Synar underage sales violations in Washington, DC. Tobacco Control 2015;24(e1):e52–e58.24570101
Kiyou Smoke Shop. Signal: the natural choice [Facebook advertisement], n.d.; <https://www.facebook.com/kiyousmokeshop/posts/new-just-in-signal-cigarettes-all-natural-native-made-brand-cigarettes/3264128723913508/>; accessed: November 10, 2022.
Knowledge@Wharton. A new marketing royalty: why digital influencers are on the rise, August 31, 2017; <http://knowledge.wharton.upenn.edu/article/new-marketing-royalty-rise-digital-influencers/>; accessed: February 12, 2019.
Kong AY, Eaddy JL, Morrison SL, Asbury D, Lindell KM, Ribisl KM. Using the Vape Shop Standardized Tobacco Assessment for Retail Settings (V-STARS) to assess product availability, price promotions, and messaging in New Hampshire vape shop retailers. Tobacco Regulatory Science 2017a;3(2):174–82.29201950
Kong AY, Golden SD, Myers AE, Little MA, Klesges R, Talcott W, Vandegrift SM, Cassidy DG, Ribisl KM. Availability, price and promotions for cigarettes and non-cigarette tobacco products: an observational comparison of U.S. Air Force bases with nearby tobacco retailers, 2016. Tobacco Control 2019;28(2):189–94.29705745
Kong AY, Golden SD, Ribisl KM, Krukowski RA, Vandegrift SM, Little MA. Cheaper tobacco product prices at U.S. Air Force Bases compared with surrounding community areas, 2019. Tobacco Control 2022a;31(e2):e169–e174.34907089
Kong G, Laestadius L, Vassey J, Majmundar A, Stroup AM, Meissner HI, Ben Taleb Z, Cruz TB, Emery SL, Romer D. Tobacco promotion restriction policies on social media. Tobacco Control 2022b.
Kong AY, Queen TL, Golden SD, Ribisl KM. Neighborhood disparities in the availability, advertising, promotion, and youth appeal of little cigars and cigarillos, United States, 2015. Nicotine & Tobacco Research 2020;22(12):2170–7.31917833
Kong G, Unger J, Baezconde-Garbanati L, Sussman S. The associations between yelp online reviews and vape shops closing or remaining open one year later. Tobacco Prevention & Cessation 2017b;2(Suppl):9.29057379
Kostygina G, Glantz SA, Ling PM. Tobacco industry use of flavours to recruit new users of little cigars and cigarillos. Tobacco Control 2016a;25(1):66–74.25354674
Kostygina G, Tran H, Shi Y, Kim Y, Emery S. “Sweeter Than a Swisher”: amount and themes of little cigar and cigarillo content on Twitter. Tobacco Control 2016b;25(Suppl 1):i75–i82.27697951
Kozlowski LT, Yost B, Stine MM, Celebucki C. Massachusetts’ advertising against light cigarettes appears to change beliefs and behavior. American Journal of Preventive Medicine 2000;18(4):339–42.10788738
Laroche M, Habibi MR, Richard M-O. To be or not to be in social media: how brand loyalty is affected by social media? International Journal of Information Management 2013;33(1):76–82.
Lavidge RJ, Steiner GA. A model for predictive measurements of advertising effectiveness. Journal of Marketing 1961;25(6):59–62.
Leatherdale ST, Strath JM. Tobacco retailer density surrounding schools and cigarette access behaviors among underage smoking students. Annals of Behavioral Medicine 2007;33(1):105–11.17291176
Lee JG, Agnew-Brune CB, Clapp JA, Blosnich JR. Out smoking on the big screen: tobacco use in LGBT movies, 2000–2011. Tobacco Control 2014;23(e2):e156–e158.24277775
Lee JG, Baker HM, Ranney LM, Goldstein AO. Neighborhood inequalities in retailers’ compliance with the Family Smoking Prevention and Tobacco Control Act of 2009, January 2014–July 2014. Preventing Chronic Disease 2015a;12:E171.26447548
Lee JG, Goldstein AO, Pan WK, Ribisl KM. Relationship between tobacco retailers’ point-of-sale marketing and the density of same-sex couples, 97 U.S. counties, 2012. International Journal of Environmental Research and Public Health 2015b;12(8):8790–810.26225987
Lee JG, Henriksen L, Rose SW, Moreland-Russell S, Ribisl KM. A systematic review of neighborhood disparities in point-of-sale tobacco marketing. American Journal of Public Health 2015c;10(5) 9:e8–e18.
Lee JG, Pan WK, Henriksen L, Goldstein AO, Ribisl KM. Is there a relationship between the concentration of same-sex couples and tobacco retailer density? Nicotine & Tobacco Research 2016;18(2):147–55.25744959
Lee JG, Sun DL, Schleicher NM, Ribisl KM, Luke DA, Henriksen L. Inequalities in tobacco outlet density by race, ethnicity and socioeconomic status, 2012, USA: results from the ASPiRE Study. Journal of Epidemiology and Community Health 2017;71(5):487–92.28249990
Lee JGL, Orlan EN, Sewell KB, Ribisl KM. A new form of nicotine retailers: a systematic review of the sales and marketing practices of vape shops. Tobacco Control 2018;27(e1):e70–e75.29208738
Legal Information Institute. Redlining, n.d.; <https://www.law.cornell.edu/wex/redlining>; accessed: December 21, 2022.
Legg T, Clift B, Gilmore AB. Document analysis of the Foundation for a Smoke-Free World’s scientific outputs and activities: a case study in contemporary tobacco industry agnogenesis. Tobacco Control 2023:tc–2022–057667.
Leibel K, Lee JG, Goldstein AO, Ranney LM. Barring intervention? lesbian and gay bars as an underutilized venue for tobacco interventions. Nicotine & Tobacco Research 2011;13(7):507–11.21498874
Lempert LK, Glantz SA. Tobacco industry promotional strategies targeting American Indians/Alaska Natives and exploiting tribal sovereignty. Nicotine & Tobacco Research 2019;21(7):940–8.29546392
Leonardi-Bee J, Nderi M, Britton J. Smoking in movies and smoking initiation in adolescents: systematic review and meta-analysis. Addiction 2016;111(10):1750–63.27043456
Lester JM, Gagosian SY. Finished with menthol: an evidence-based policy option that will save lives. Journal of Law, Medicine & Ethics 2017;45(1 Suppl):41–44.
Levin M. Lorillard, other tobacco companies use politics to protect menthol brands. News and Record, November 17, 2015; <https://www.greensboro.com/business/local_business/lorillard-other-tobacco-companies-use-politics-to-protect-menthol-brands/article_978cc94f-1808-58b0-af26-b205e7402ae2.html/>; accessed: February 12, 2019.
Levin M. R.J. Reynolds is fighting moves to ban menthol cigarettes by enlisting black leaders—and stoking fears of police harassment. MinnPost, February 2, 2017; <https://www.minnpost.com/politics-policy/2017/02/rj-reynolds-fighting-moves-ban-menthol-cigarettes-enlisting-black-leaders-an>; accessed: February 12, 2019.
Levy DT, Chaloupka F, Gitchell J. The effects of tobacco control policies on smoking rates: a tobacco control scorecard. Journal of Public Health Management and Practice 2004;10(4):338–53.15235381
Levy DT, Chaloupka F, Lindblom EN, Sweanor DT, O’Connor RJ, Shang C, Borland R. The U.S. cigarette industry: an economic and marketing perspective. Tobacco Regulatory Science 2019;5(2):156–68.32864394
Liang B, Scammon DL. Incidence of online health information search: a useful proxy for public health risk perception. Journal of Medical Internet Research 2013;15(6):e114.23773974
Liang Y, Zheng X, Zeng DD, Zhou X, Leischow SJ, Chung W. Exploring how the tobacco industry presents and promotes itself in social media. Journal of Medical Internet Research 2015;17(1):e24.25608524
Liber AC, Sánchez-Romero LM, Cadham CJ, Yuan Z, Li Y, Oh H, Cook S, Warner KE, Henriksen L, Mistry R, . Tobacco couponing: a systematic review of exposures and effects on tobacco initiation and cessation. Nicotine & Tobacco Research 2021;24(10):1523–33.
Lienemann BA, Rose SW, Unger JB, Meissner HI, Byron MJ, Baezconde-Garbanati L, Huang LL, Cruz TB. Tobacco advertisement liking, vulnerability factors, and tobacco use among young adults. Nicotine & Tobacco Research 2019;21(3):300–8.30329102
Ling PM, Haber LA, Wedl S. Branding the rodeo: a case study of tobacco sports sponsorship. American Journal of Public Health 2010;100(1):32–41.19910357
Lisha NE, Jordan JW, Ling PM. Peer crowd affiliation as a segmentation tool for young adult tobacco use. Tobacco Control 2016;25(Suppl 1):i83–i89.27697952
Liu ST, Snyder K, Tynan MA, Wang TW. Youth access to tobacco products in the United States, 2016–2018. Tobacco Regulatory Science 2019;5(6):491–501.31745494
Loomis BR, Kim AE, Goetz JL, Juster HR. Density of tobacco retailers and its association with sociodemographic characteristics of communities across New York. Public Health 2013;127(4):333–8.23515009
Loukas A, Lewis MJ, Marti CN, Pasch KE, Perry CL. Tobacco magazine advertising impacts longitudinal changes in the number of tobacco products used by young adults. Journal of Adolescent Health 2021;68(4):773–9.
Lovato C, Watts A, Stead LF. Impact of tobacco advertising and promotion on increasing adolescent smoking behaviours. Cochrane Database of Systematic Reviews 2011, Issue 10. Art. No: CD003439. DOI: 10.1002/14651858.CD003439.pub2.
Lucy. Take a break through [online advertisement by Lucy brand nicotine pouches], n.d.; <https://lucy.co/>; accessed: November 10, 2022.
Luke D, Esmundo E, Bloom Y. Smoke signs: patterns of tobacco billboard advertising in a metropolitan region. Tobacco Control 2000;9(1):16–23.10691754
Luo X, Bhattacharya CB. Corporate social responsibility, customer satisfaction, and market value. Journal of Marketing 2006;70(4):1–18.
Lyu JC, Huang P, Jiang N, Ling PM. A systematic review of e-cigarette marketing communication: messages, communication channels, and strategies. International Journal of Environmental Research and Public Health 2022;19(15):9263.35954623
MAB. Discussion Paper Total Minority Marketing Plan. September 7, 1984. Brown & Williamson Records Collection. Bates No. 531000141-531000144. <https://www.industrydocuments.ucsf.edu/docs/xgbw0138>.
MacKenzie SB, Lutz RJ, Belch GE. The role of attitude toward the ad as a mediator of advertising effectiveness: a test of competing explanations. Journal of Marketing Research 1986;23(2):130.
Mackey TK, Miner A, Cuomo RE. Exploring the e-cigarette e-commerce marketplace: identifying internet e-cigarette marketing characteristics and regulatory gaps. Drug and Alcohol Dependence 2015;156:97–103.26431794
Mangun K, Perry EL Jr. The Negro/National Newspaper Publishers Association and its dual roles as a trade and advocacy organization 1940–2020. Journalism & Communication Monographs 2020;22(4):264–336.
Mantey DS, Cooper MR, Clendennen SL, Pasch KE, Perry CL. E-cigarette marketing exposure is associated with e-cigarette use among U.S. youth. Journal of Adolescent Health 2016;58(6):686–90.
Marynak K, Gentzke A, Wang TW, Neff L, King BA. Exposure to electronic cigarette advertising among middle and high school students—United States, 2014–2016. Morbidity and Mortality Weekly Report 2018;67(10):294–9.29543786
Marynak KL, Robichaud MO, Puryear T, Kennedy RD, Moran MB. #Nicotineaddiction on TikTok: A quantitative content analysis of top-viewed posts. Tobacco Induced Diseases 2022;20:69.35979474
Mayers RS, Wiggins LL, Fulghum FH, Peterson NA. Tobacco outlet density and demographics: a geographically weighted regression analysis. Prevention Science 2012;13(5):462–71.22538505
McCandless PM, Yerger VB, Malone RE. Quid pro quo: tobacco companies and the Black press. American Journal of Public Health 2012;102(4):739–50.21852652
McCarthy M. E-cigarette companies target youth, U.S. congressional study finds. BMJ 2014;348:g2871.24755576
McCarthy WJ, Mistry R, Lu Y, Patel M, Zheng H, Dietsch B. Density of tobacco retailers near schools: effects on tobacco use among students. American Journal of Public Health 2009;99(11):2006–13.19820214
McDaniel PA, Cadman B, Malone RE. Shared vision, shared vulnerability: A content analysis of corporate social responsibility information on tobacco industry websites. Preventive Medicine 2016;89:337–44.27261411
McDaniel PA, Lown EA, Malone RE. U.S. media coverage of tobacco industry corporate social responsibility initiatives. Journal of Community Health 2018;43(1):117–27.28685318
McDaniel PA, Malone RE. “What is our story?” Philip Morris’s changing corporate narrative. American Journal of Public Health 2015;105(10):e68–e75.26270280
McDonald B. Tobacco prices to change throughout DOD, March 30, 2017; <https://www.beaufort.marines.mil/COMMSTRAT/News/News-View/Article/1135642/tobacco-prices-to-change-throughout-dod/>; accessed: November 13, 2023.
McKee M, Stuckler D. Revising the corporate and commercial determinants of health. American Journal of Public Health 2018;108(9):1167–70.30024808
Michikyan M, Suárez-Orozco C. Adolescent media and social media use. Journal of Adolescent Research 2016;31(4):411–4.
Mickle T, Brent K. Reynolds-Lorillard deal to close June 12. The Wall Street Journal, June 8, 2015; <https://www.wsj.com/articles/reynolds-lorillard-deal-clears-final-hurdle-as-judge-grants-approval-1433775827>; accessed: October 4, 2022.
Miller Lo EJ, Young WJ, Ganz O, Talbot EM, O’Connor RJ, Delnevo CD. Trends in overall and menthol market shares of leading cigarette brands in the U.S.A.: 2014–2019. International Journal of Environmental Research and Public Health 2022;19(4):2270.35206458
Mills SD, Golden SD, Henriksen L, Kong AY, Queen TL, Ribisl KM. Neighbourhood disparities in the price of the cheapest cigarettes in the USA. Journal of Epidemiology and Community Health 2019;73(9):894–6.31122944
Mills SD, Henriksen L, Golden SD, Kurtzman R, Kong AY, Queen TL, Ribisl KM. Disparities in retail marketing for menthol cigarettes in the United States, 2015. Health & Place 2018;53:62–70.30055469
Mills SD, Kong AY, Reimold AE, Baggett CD, Wiesen CA, Golden SD. Sociodemographic disparities in tobacco retailer density in the United States, 2000–2017. Nicotine & Tobacco Research 2022;24(8):1291–9.35079790
Moran MB, Heley K, Baldwin K, Xiao C, Lin V, Pierce JP. Selling tobacco: A comprehensive analysis of the U.S. tobacco advertising landscape. Addictive Behaviors 2019a;96:100–9.31071602
Moran MB, Heley K, Pierce JP, Niaura R, Strong D, Abrams D. Ethnic and socioeconomic disparities in recalled exposure to and self-reported impact of tobacco marketing and promotions. Health Communication 2019b;34(3):280–9.29236530
Morgenstern M, Stoolmiller M, Bergamini E, Sargent JD. Did limits on payments for tobacco placements in U.S. movies affect how movies are made? Tobacco Control 2017;26(1):105–8.26822189
Morley CP, Cummings KM, Hyland A, Giovino GA, Horan JK. Tobacco Institute lobbying at the state and local levels of government in the 1990s. Tobacco Control 2002;11 (Suppl 1):I102–I109.11893820
Morton T. U.S. Smokeless won’t have signs at CNFR, but still gives nearly $300,000. Casper Star-Tribune, June 24, 2009.
Muehling DD. An investigation of factors underlying attitude-toward-advertising-in-general. Journal of Advertising 1987;16(1):32–40.
Muggli ME, Pollay RW, Lew R, Joseph AM. Targeting of Asian Americans and Pacific Islanders by the tobacco industry: results from the Minnesota Tobacco Document Depository. Tobacco Control 2002;11(3):201–9.12198269
Mulder J, Ter Bogt TF, Raaijmakers QA, Gabhainn SN, Monshouwer K, Vollebergh WA. The soundtrack of substance use: music preference and adolescent smoking and drinking. Substance Use & Misuse 2009;44(4):514–31.19283623
Mulder J, Ter Bogt TF, Raaijmakers QA, Nic Gabhainn S, Monshouwer K, Vollebergh WA. Is it the music? Peer substance use as a mediator of the link between music preferences and adolescent substance use. Journal of Adolescence 2010;33(3):387–94.19818488
National Association for the Advancement of Colored People. NAACP president Derrick Johnson on FDA’s move to ban menthol [press statement], April 28, 2022a; <https://naacp.org/articles/naacp-president-derrick-johnson-fdas-move-ban-menthol>; accessed: August 30, 2023.
National Association for the Advancement of Colored People. NAACP writes letter urging FDA to ban menthol flavored cigarettes and flavored cigar products [press statement], April 20, 2022b; <https://naacp.org/articles/naacp-writes-letter-urging-fda-ban-menthol-flavored-cigarettes-and-flavored-cigar-products>; accessed: September 5, 2023.
National Cancer Institute. The Role of the Media in Promoting and Reducing Tobacco Use. Tobacco Control Monograph No. 19. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2008. NIH Publication No. 07-6242.
National Cancer Institute and World Health Organization. The Economics of Tobacco and Tobacco Control. Tobacco Control Monograph 21. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute; and Geneva (Switzerland): World Health Organization, 2016. NIH Publication No. 16-CA-8029A.
National Native Network. Keep it sacred, n.d.; <https://keepitsacred.itcmi.org/>; accessed: July 17, 2023.
Navarro JG. Advertising in the United States—statistics and facts, January 6, 2023; <https://www.statista.com/topics/979/advertising-in-the-us/#topicOverview>; accessed: February 10, 2023.
New York State, Department of State, Division of Corporations. Certificate of amended name from Foundation for a Smoke-free World, Inc. to Global Action to End Smoking, Inc. [corporation and business entity database], n.d.; <https://apps.dos.ny.gov/publicInquiry/>; accessed: February 23, 2024.
Nguyen AB, Robinson J, O’Brien EK, Zhao X. Racial and ethnic differences in tobacco information seeking and information sources: findings from the 2015 Health Information National Trends Survey. Journal of Health Communication 2017;22(9):743–52.28762887
Nicopure Labs, LLC v. U.S. Food and Drug Administration, 944 F.3d 267 (D.C. Cir. 2019).
Niederdeppe J, Farrelly MC, Wenter D. Media advocacy, tobacco control policy change and teen smoking in Florida. Tobacco Control 2007;16(1):47–52.17297073
Nixon ML, Mahmoud L, Glantz SA. Tobacco industry litigation to deter local public health ordinances: the industry usually loses in court. Tobacco Control 2004;13(1):65–73.14985600
Noar SM. A health educator’s guide to theories of health behavior. International Quarterly of Community Health Education 2005;24(1):75–92.17690053
North Coast Journal. Billboards decry use of Indian Images. North Coast Journal Weekly, March 27, 2003; <https://www.northcoastjournal.com/032703/news0327.html#anchor624790>; accessed: July 17, 2023.
Novak SP, Reardon SF, Raudenbush SW, Buka SL. Retail tobacco outlet density and youth cigarette smoking: a propensity-modeling approach. American Journal of Public Health 2006;96(4):670–6.16507726
O’Brien EK, Hoffman L, Navarro MA, Ganz O. Social media use by leading U.S. e-cigarette, cigarette, smokeless tobacco, cigar and hookah brands. Tobacco Control 2020;29(e1):e87–e97.32217772
Obermiller C. Varieties of mere exposure: the effects of processing style and repetition on affective response. Journal of Consumer Research 1985;12(1):17.
Offen N, Smith EA, Malone RE. Is tobacco a gay issue? Interviews with leaders of the lesbian, gay, bisexual and transgender community. Culture, Health & Sexuality 2008;10(2):143–57.
Ong MK, Zhou Q, Sung H-Y. Sensitivity to cigarette prices among individuals with alcohol, drug, or mental disorders. American Journal of Public Health 2010;100(7):1243–5.20466972
OpenSecrets. Tobacco PACs contributions to candidates, 2019–2020, 2021; <https://www.opensecrets.org/political-action-committees-pacs/industry-detail/A02/2020>; accessed: July 28, 2023.
Osman A, Queen T, Choi K, Goldstein AO. Receipt of direct tobacco mail/email coupons and coupon redemption: demographic and socioeconomic disparities among adult smokers in the United States. Preventive Medicine 2019;126:105778.31323282
Padon AA, Maloney EK, Cappella JN. Youth-targeted e-cigarette marketing in the U.S. Tobacco Regulatory Science 2017;3(1):95–101.28083545
Papaleontiou L, Agaku IT, Filippidis FT. Effects of exposure to tobacco and electronic cigarette advertisements on tobacco use: an analysis of the 2015 National Youth Tobacco Survey. Journal of Adolescent Health 2020;66(1):64–71.
Peiper N, Aramburu C, Thompson K, Abadi M. Differential patterns of e-cigarette and tobacco marketing exposures among youth: associations with substance use and tobacco prevention strategies. International Journal on Drug Policy 2020;86:102925.33217687
Pericot-Valverde I, Elliott RJ, Miller ME, Tidey JW, Gaalema DE. Posttraumatic stress disorder and tobacco use: a systematic review and meta-analysis. Addictive Behaviors 2018;84:238–47.29753221
Persoskie A, Donaldson EA, Ryant C. How tobacco companies have used package quantity for consumer targeting. Tobacco Control 2019;28:365–73.
Pew Research Center. Internet/broadband fact sheet, 2021a; <https://www.pewresearch.org/internet/fact-sheet/internet-broadband/>; accessed: May 20, 2022.
Pew Research Center. Social media fact sheet, 2021b; <https://www.pewresearch.org/internet/fact-sheet/social-media/>; accessed: April 5, 2023.
Pickett J. Kool Mix Nights. April 6, 1998. Brown & Williamson Records Collection; Master Settlement Agreement Collection. Bates No. 210430224/0228. <https://www.industrydocuments.ucsf.edu/docs/kkxj0081>.
Pierce JP, Choi WS, Gilpin EA, Farkas AJ, Berry CC. Tobacco industry promotion of cigarettes and adolescent smoking. JAMA: the Journal of the American Medical Association 1998;279(7):511–5.9480360
Pierce JP, Farkas AJ, Evans N, Gilpin E. An improved surveillance measure for adolescent smoking? Tobacco Control 1995;4(Suppl 1):S47–S56.
Pierce JP, Sargent JD, Portnoy DB, White M, Noble M, Kealey S, Borek N, Carusi C, Choi K, Green VR, . Association between receptivity to tobacco advertising and progression to tobacco use in youth and young adults in the PATH Study. JAMA Pediatrics 2018;172(5):444–51.29582078
Pierce JP, Sargent JD, White MM, Borek N, Portnoy DB, Green VR, Kaufman AR, Stanton CA, Bansal-Travers M, Strong DR, . Receptivity to tobacco advertising and susceptibility to tobacco products. Pediatrics 2017;139(6):e20163353.28562266
Pokhrel P, Fagan P, Herzog TA, Laestadius L, Buente W, Kawamoto CT, Lee HR, Unger JB. Social media e-cigarette exposure and e-cigarette expectancies and use among young adults. Addictive Behaviors 2018;78:51–8.29127784
Pokhrel P, Herzog TA, Fagan P, Unger JB, Stacy AW. E-cigarette advertising exposure, explicit and implicit harm perceptions, and e-cigarette use susceptibility among non-smoking young adults. Nicotine & Tobacco Research 2019;21(1):127–31.29444275
Pokorny SB, Jason LA, Schoeny ME. The relation of retail tobacco availability to initiation and continued smoking. Journal of Clinical Child and Adolescent Psychology 2003;32(2):193–204.12679277
Polansky JR, Driscoll D, Glantz SA. Smoking in top-grossing U.S. movies: 2019, 2020; <https://escholarship.org/uc/item/86q9w25v>; accessed: February 24, 2023.
Portugal C, Cruz TB, Espinoza L, Romero M, Baezconde-Garbanati L. Countering tobacco industry sponsorship of Hispanic/Latino organizations through policy adoption: a case study. Health Promotion Practice 2004; 5(3 Suppl):143S–156S.15231108
Poston WS, Jahnke SA, Haddock CK, Hyder ML, Taylor JE, Lando HA, Kaipust CM. Menthol cigarette pricing at military and community retail outlets in the United States. BMC Public Health 2012;12(1):731.22938755
Primack BA, Bost JE, Land SR, Fine MJ. Volume of tobacco advertising in African American markets: systematic review and meta-analysis. Public Health Reports 2007;122(5):607–15.17877308
Primack BA, Rice KR, Shensa A, Carroll MV, DePenna EJ, Nakkash R, Barnett TE. U.S. hookah tobacco smoking establishments advertised on the internet. American Journal of Preventive Medicine 2012;42(2):150–6.22261211
Prochaska JJ, Das S, Young-Wolff KC. Smoking, mental illness, and public health. Annual Review of Public Health 2017;38:165–85.
Prochaska JJ, Hall SM, Bero LA. Tobacco use among individuals with schizophrenia: what role has the tobacco industry played? Schizophrenia Bulletin 2008;34(3):555–67.17984298
Pu J, Zhang X. Exposure to advertising and perception, interest, and use of e-cigarettes among adolescents: findings from the U.S. National Youth Tobacco Survey. Perspectives in Public Health 2017;137(6):322–5.28379069
Public Health Cigarette Smoking Act of 1969, Public Law 91–222, 84 U.S. Statutes at Large 87 (1970), codified at 15 U.S. Code § 1335.
Public Health Law Center. Litigation tracker, n.d.a; <https://www.publichealthlawcenter.org/litigation-tracker>; accessed: July 28, 2023.
Public Health Law Center. Master Settlement Agreement, n.d.b; <https://www.publichealthlawcenter.org/sites/default/files/resources/master-settlement-agreement.pdf>; accessed: February 20, 2019.
Quillian L. Segregation and poverty concentration: the role of three segregations. American Sociological Review 2012;77(3):354–79.24648570
R.J. Reynolds Records Collection. Hispanic Market Learning. 1989. R.J. Reynolds Records Collection. Bates No. 507135127-507135159. <https://www.industrydocuments.ucsf.edu/docs/pmpw0087>
R.J. Reynolds Records Collection. Project SCUM. December 12, 1995. R.J. Reynolds Records Collection. Bates No. 518021121-518021129. <https://www.industrydocuments.ucsf.edu/docs/sfck0098>
R.J. Reynolds Tobacco Co. v. U.S. Food & Drug Administration, 696 F.3d 1205 (D.C. Cir. 2012).
R.J. Reynolds Tobacco Co. v. U.S. Food & Drug Administration, No. 6:20-CV-00176, 2022 WL 17489170, (E.D. Tex. Dec. 7, 2022), appeal docketed, No. 23-40076 (5th Cir. Feb. 6, 2023).
Ramirez A, Walther JB, Burgoon JK, Sunnafrank M. Information-seeking strategies, uncertainty, and computer-mediated communication. Human Communication Research 2002;28(2):213–28.
Raymond N. U.S. Supreme Court lets California ban flavored tobacco products, December 12 2022; <https://www.reuters.com/legal/us-supreme-court-lets-california-ban-flavored-tobacco-products-2022-12-12/>; accessed: July 28, 2023.
Raymond N. U.S. Supreme Court rejects challenge to California flavored tobacco ban, January 8, 2024; <https://www.reuters.com/legal/us-supreme-court-rejects-challenge-california-flavored-tobacco-ban-2024-01-08/>; accessed: February 23, 2024.
Reid RJ, Morton CM, Garcia-Reid P, Peterson NA, Yu D. Examining tobacco outlet concentration in New Jersey: does income and ethnicity matter? Journal of Ethnicity in Substance Abuse 2013;12(3):197–209.23967882
Reitzel LR, Cromley EK, Li Y, Cao Y, Dela Mater R, Mazas CA, Cofta-Woerpel L, Cinciripini PM, Wetter DW. The effect of tobacco outlet density and proximity on smoking cessation. American Journal of Public Health 2011;101(2):315–20.21164089
Research Resources. An Exploratory Study Conducted Among U.S. Hispanics. February 1988. R.J. Reynolds Records Collection. Bates No. 507185495-507185529. <http://legacy.library.ucsf.edu/tid/len54d00>.
Reynolds American. Santa Fe Natural Tobacco Company Foundation, n.d.; <https://www.reynoldsamerican.com/santa-fe-foundation>; accessed: March 4, 2024.
Reynolds American. Enhance Responsibility/ Improve Credibility/ Increase Sustainability: 2008 Corporate Social Responsibility Report. January 23, 2009. R.J. Reynolds Records Collection. Bates No. 557091063-557091124. <https://www.industrydocumentslibrary.ucsf.edu/tobacco/docs/fpml0222>.
Ribisl KM, D’Angelo H, Feld AL, Schleicher NC, Golden SD, Luke DA, Henriksen L. Disparities in tobacco marketing and product availability at the point of sale: results of a national study. Preventive Medicine 2017a;105:381–8.28392252
Ribisl KM, Luke DA, Bohannon DL, Sorg AA, Moreland-Russell S. Reducing disparities in tobacco retailer density by banning tobacco product sales near schools. Nicotine & Tobacco Research 2017b;19(2):239–44.27613900
Richardson A, Ganz O, Pearson J, Celcis N, Vallone D, Villanti AC. How the industry is marketing menthol cigarettes: the audience, the message and the medium. Tobacco Control 2015a;24(6):594–600.25178275
Richardson A, Ganz O, Vallone D. The cigar ambassador: how Snoop Dogg uses Instagram to promote tobacco use. Tobacco Control 2014;23(1):79–80.23748187
Richardson A, Ganz O, Vallone D. Tobacco on the web: surveillance and characterisation of online tobacco and e-cigarette advertising. Tobacco Control 2015b;24(4):341–7.24532710
Richardson A, Vallone DM. YouTube: a promotional vehicle for little cigars and cigarillos? Tobacco Control 2014;23(1):21–6.23047887
Richmond Jazz Festival at Maymont. Richmond Jazz Festival announces 2018 lineup, May 24, 2018; <https://richmondjazzandmusicfestival.com/press-release.pdf>; accessed: July 18, 2023.
Roberts ME, Berman ML, Slater MD, Hinton A, Ferketich AK. Point-of-sale tobacco marketing in rural and urban Ohio: could the new landscape of tobacco products widen inequalities? Preventive Medicine 2015;81:232–5.26363447
Robertson L, McGee R, Marsh L, Hoek J. A systematic review on the impact of point-of-sale tobacco promotion on smoking. Nicotine & Tobacco Research 2015;17(1):2–17.25173775
Robinson RG, Barry M, Bloch M, Glantz S, Jordan J, Murray KB, Popper E, Sutton C, Tarr-Whelan K, Themba M, . Report of the Tobacco Policy Research Group on marketing and promotions targeted at African Americans, Latinos, and women. Tobacco Control 1992;1(Suppl 1):S24–S30.
Rodriguez D, Carlos HA, Adachi-Mejia AM, Berke EM, Sargent J. Retail tobacco exposure: using geographic analysis to identify areas with excessively high retail density. Nicotine & Tobacco Research 2014;16(2):155–65.23999651
Rodriguez D, Carlos HA, Adachi-Mejia AM, Berke EM, Sargent JD. Predictors of tobacco outlet density nationwide: a geographic analysis. Tobacco Control 2013;22(5):349–55.22491038
Rogers ES, Vargas EA. Tobacco retail environment near housing programmes for patients with mental health conditions in New York City. Tobacco Control 2018;27(5):526–33.28855299
Rose SW, Barker DC, Angelo H, Khan T, Huang J, Chaloupka FJ, Ribisl KM. The availability of electronic cigarettes in U.S. retail outlets, 2012: results of two national studies. Tobacco Control 2014;23(Suppl 3): iii10–iii16.24935892
Rose SW, Glasser AM, Zhou Y, Cruz TB, Cohn AM, Lienemann BA, Byron MJ, Huang L-L, Meissner HI, Baezconde-Garbanati L, . Adolescent tobacco coupon receipt, vulnerability characteristics and subsequent tobacco use: analysis of PATH Study, Waves 1 and 2. Tobacco Control 2018;27(e1):e50–e56.29472444
Rose SW, Jo CL, Binns S, Buenger M, Emery S, Ribisl KM. Perceptions of menthol cigarettes among Twitter users: content and sentiment analysis. Journal of Medical Internet Research 2017;19(2):e56.28242592
Rose SW, Myers AE, D’Angelo H, Ribisl KM. Retailer adherence to Family Smoking Prevention and Tobacco Control Act, North Carolina, 2011. Preventing Chronic Disease 2013;10:E47.23557638
Ross H, Tesche J, Vellios N. Undermining government tax policies: common legal strategies employed by the tobacco industry in response to tobacco tax increases. Preventive Medicine 2017;105S(Suppl):S19–S22.28625418
Rust SM, Myers AE, D’Angelo H, Queen TL, Laska MN, Ribisl KM. Tobacco marketing at SNAP- and WIC-authorized retail food stores in the United States. Health Education & Behavior 2019;46(4):541–9.30829070
Rutherford BN, Sun T, Lim CCW, Chung J, Cheng B, Davidson L, Tisdale C, Leung J, Stjepanovic D, Connor JP, . Changes in viewer engagement and accessibility of popular vaping videos on TikTok: a 12-month prospective study. International Journal of Environmental Research and Public Health 2022;19(3):1141.35162170
Saffer H, Chaloupka F. The effect of tobacco advertising bans on tobacco consumption. Journal of Health Economics 2000;19(6):1117–37.11186847
Samet JM, Wipfli HL. Ending the tobacco epidemic: from the genetic to the global level. In: Sommer M, Parker R, editors. Structural Approaches to Public Health. London: Routledge, 2013.
Sanders-Jackson A, Parikh NM, Schleicher NC, Fortmann SP, Henriksen L. Convenience store visits by U.S. adolescents: rationale for healthier retail environments. Health & Place 2015;34:63–6.25955537
Santa Fe Natural Tobacco Company Foundation. [Website banner], 2023; <https://www.sfntcfoundation.org>; accessed: March 7, 2023.
Savona D. The Jonas effect: cigar lover Nick Jonas is in the midst of a very busy year, with several films, a hit album and a long-awaited reunion tour with his brothers, September 2019; <https://www.cigaraficionado.com/article/the-jonas-effect>; accessed: December 21, 2022.
Sawdey MD, Hancock L, Messner M, Prom-Wormley EC. Assessing the association between e-cigarette use and exposure to social media in college students: a cross-sectional study. Substance Use & Misuse 2017;52(14):1910–7.28777682
Schneider JE, Reid RJ, Peterson NA, Lowe JB, Hughey J. Tobacco outlet density and demographics at the tract level of analysis in Iowa: implications for environmentally based prevention initiatives. Prevention Science 2005;6(4):319–25.16163568
Schwartz E, Onnen N, Craigmile PF, Roberts ME. The legacy of redlining: associations between historical neighborhood mapping and contemporary tobacco retailer density in Ohio. Health & Place 2021;68:102529.33631601
Secretary of the Air Force. Air Force Instruction 48-104 Aerospace Medicine Tobacco Free Living, July 11, 2019; <https://static.e-publishing.af.mil/production/1/af_sg/publication/afi48-104/afi48-104.pdf>; accessed: November 4, 2022.
Seidenberg AB, Caughey RW, Rees VW, Connolly GN. Storefront cigarette advertising differs by community demographic profile. American Journal of Health Promotion 2010;24(6):e26–e31.20594091
Shadel WG, Martino SC, Setodji C, Scharf D. Momentary effects of exposure to prosmoking media on college students’ future smoking risk. Health Psychology 2012;31(4):460–6.22353027
Shan L, Azagba S. Longitudinal associations of tobacco-related social media involvement with cigarette and e-cigarette initiation among U.S. adolescents. European Journal of Pediatrics 2022;181(1):189–96.34240227
Sharma A, Fix BV, Delnevo C, Cummings KM, Connor RJ. Trends in market share of leading cigarette brands in the U.S.A.: National Survey on Drug Use and Health 2002–2013. BMJ Open 2016;6(1):e008813.
Sheehan DM. Marketing little cigars and cigarillos in African American communities. American Journal of Public Health 2014;104(4):e1.
Siahpush M, Farazi PA, Kim J, Michaud TL, Yoder AM, Soliman G, Tibbits MK, Nguyen MN, Shaikh RA. Social disparities in exposure to point-of-sale cigarette marketing. International Journal of Environmental Research and Public Health 2016;13(12):E1263.
Siahpush M, Jones PR, Singh GK, Timsina LR, Martin J. Association of availability of tobacco products with socio-economic and racial/ethnic characteristics of neighbourhoods. Public Health 2010a;124(9):525–9.20723950
Siahpush M, Jones PR, Singh GK, Timsina LR, Martin J. The association of tobacco marketing with median income and racial/ethnic characteristics of neighbourhoods in Omaha, Nebraska. Tobacco Control 2010b;19(3):256–8.20395407
Signal. Tribe members get $10 back [online advertisement], n.d.; <https://www.signaltobacco.com/join-the-tribe>; accessed: November 10, 2022.
Simon P, Camenga DR, Morean ME, Kong G, Bold KW, Cavallo DA, Krishnan-Sarin S. Socioeconomic status and adolescent e-cigarette use: the mediating role of e-cigarette advertisement exposure. Preventive Medicine 2018;112:193–8.29673887
Singh T, Agaku IT, Arrazola RA, Marynak KL, Neff LJ, Rolle IT, King BA. Exposure to advertisements and electronic cigarette use among U.S. middle and high school students. Pediatrics 2016a;137(5):e20154155.27244815
Singh T, Marynak K, Arrazola RA, Cox S, Rolle IV, King BA. Vital signs: exposure to electronic cigarette advertising among middle school and high school students—United States, 2014. Morbidity and Mortality Weekly Report 2016b;64(52):1403–8.26741522
Slater MD. Persuasion processes across receiver goals and message genres. Communication Theory 1997; 7(2):125–48.
Slater MD. Reinforcing spirals: the mutual influence of media selectivity and media effects and their impact on individual behavior and social identity. Communication Theory 2007;17(3):281–303.
Smith J, Thompson S, Lee K. “Public enemy no. 1”: tobacco industry funding for the AIDS response. SAHARA: Journal of Social Aspects of HIV/AIDS Research Alliance 2016;13(1):41–52.
Smith KE, Savell E, Gilmore AB. What is known about tobacco industry efforts to influence tobacco tax? A systematic review of empirical studies. Tobacco Control 2013;22(2):144–53.22887175
Soneji S, Ambrose BK, Lee W, Sargent J, Tanski S. Direct-to-consumer tobacco marketing and its association with tobacco use among adolescents and young adults. Journal of Adolescent Health 2014;55(2):209–15.
Soneji S, Knutzen KE, Tan ASL, Moran MB, Yang J, Sargent J, Choi K. Online tobacco marketing among U.S. adolescent sexual, gender, racial, and ethnic minorities. Addictive Behaviors 2019a;95:189–96.30954888
Soneji S, Pierce JP, Choi K, Portnoy DB, Margolis KA, Stanton CA, Moore RJ, Bansal-Travers M, Carusi C, Hyland A, . Engagement with online tobacco marketing and associations with tobacco product use among U.S. youth. Journal of Adolescent Health 2017;61(1):61–9.
Soneji S, Yang J, Knutzen KE, Moran MB, Tan ASL, Sargent J, Choi K. Online tobacco marketing and subsequent tobacco use. Pediatrics 2018;141(2):e20172927.29295893
Soneji S, Yang J, Moran MB, Tan ASL, Sargent J, Knutzen KE, Choi K. Engagement with online tobacco marketing among adolescents in the United States: 2013–2014 to 2014–2015. Nicotine & Tobacco Research 2019b;21(7):918–25.29741711
Southwell BG, Barmada CH, Hornik RC, Maklan DM. Can we measure encoded exposure? validation evidence from a national campaign. Journal of Health Communication 2002;7(5):445–53.12455763
Stanford Research into the Impact of Tobacco Advertising. Three priorities [advertisement by Copenhagen brand smokeless tobacco], 2003; <https://tobacco.stanford.edu/chew/ing19006/>; accessed: November 10, 2022.
Stanford Research into the Impact of Tobacco Advertising. April [magazine advertisement/calendar by Longhorn brand smokeless tobacco], 2006; <https://tobacco.stanford.edu/chew/img35827/>; accessed: November 10, 2022.
Stanford Research into the Impact of Tobacco Advertising. It’s what’s inside [advertisement by Copenhagen brand smokeless tobacco], 2008; <https://tobacco.stanford.edu/chew/ing23687/>; accessed: November 10, 2022.
Stanford Research into the Impact of Tobacco Advertising. Starbuzz hookah tobacco: exotic Asian persuasion [photograph showing artwork on a tobacco product], 2016a; <https://tobacco.stanford.edu/hookahs/starbuzz/#collection-256>; accessed: November 10, 2022.
Stanford Research into the Impact of Tobacco Advertising. Wednesdays college night [online advertisement by Starbuzz Hookah Lounge], 2016b; <https://tobacco.stanford.edu/hookah/img37098/>; accessed: November 10, 2022.
Stanford Research into the Impact of Tobacco Advertising. All smiles for Sweets [Instagram post by Swisher Sweets brand cigars], 2018; <https://tobacco.stanford.edu/cigar/img38428/>; accessed: November 10, 2022.
Stanford Research into the Impact of Tobacco Advertising. ZYN summer tour [Instagram post by ZYN brand nicotine pouches], 2019; <https://tobacco.stanford.edu/pouches_gums/pouches-major/zyn/#collection-175>; accessed: November 10, 2022.
Stanford Research into the Impact of Tobacco Advertising. Puffbar official [Instagram post by Puffbar], 2020; <https://tobacco.stanford.edu/disposable/img41505/>; accessed: November 10, 2022.
Stanford Research into the Impact of Tobacco Advertising. IndianHead: real Indian tobacco e-liquid [brand logo for IndianHead brand tobacco e-liquid], 2021; <https://tobacco.stanford.edu/ecig/img24463/>; accessed: November 10, 2022.
Stanford Research into the Impact of Tobacco Advertising. Discover intensity reimagined [Kool website image for non-menthol tobacco cigarettes], 2022; <https://tobacco.stanford.edu/cigarettes/menthol-medicates/nonmenthol/#collection-32>; accessed: April 7, 2023.
Stanford Research into the Impact of Tobacco Advertising. Be smooth [advertisement by Kool brand cigarettes], n.d.a; <https://tobacco.stanford.edu/cigarette/img13200/>; accessed: November 10, 2022.
Stanford Research into the Impact of Tobacco Advertising. Want to go somewhere you’ve never been before? [advertisement by Camel Crush brand mentholated squeezers], n.d.b; <https://tobacco.stanford.edu/cigarette/squeeze_26-jpg/>; accessed: November 10, 2022.
Stevens P, Carlson LM, Hinman JM. An analysis of tobacco industry marketing to lesbian, gay, bisexual, and transgender (LGBT) populations: strategies for mainstream tobacco control and prevention. Health Promotion Practice 2004;53 (Suppl 1):129S–134S.
Stockton B. Detroit pastor says he was offered $250,000 to oppose menthol cigarette ban, August 25, 2023; <https://www.freep.com/story/news/local/michigan/2022/08/25/detroit-pastor-says-he-offered-250-k-oppose-menthol-cigarette-ban/7866711001/>; accessed: September 5, 2023.
Storey K. Nick Jonas is really ‘pumped’ about becoming the first person under 30 to hold a cigar on the cover of Cigar Aficionado, 2019; <https://metro.co.uk/2019/09/10/nick-jonas-really-pumped-becoming-first-person-30-hold-cigar-cover-cigar-aficionado-10714238/>; accessed: November 10, 2022.
Substance Abuse and Mental Health Services Administration. Adults With Mental Illness or Substance Use Disorder Account for 40 Percent of All Cigarettes Smoked, March 20, 2013; <https://www.samhsa.gov/data/sites/default/files/spot104-cigarettes-mental-illness-substance-use-disorder/spot104-cigarettes-mental-illness-substance-use-disorder.pdf>; accessed: October 4, 2022.
Sun T, Lim CCW, Chung J, Cheng B, Davidson L, Tisdale C, Leung J, Gartner CE, Connor J, Hall WD, . Vaping on TikTok: a systematic thematic analysis. Tobacco Control 2023;32(2):251–4.34312317
Sutton CD, Robinson RG. The marketing of menthol cigarettes in the United States: populations, messages, and channels. Nicotine & Tobacco Research 2004; (6 Suppl 1):S83–S91.14982711
Tan ASL, Bigman CA. Misinformation about commercial tobacco products on social media-implications and research opportunities for reducing tobacco-related health disparities. American Journal of Public Health 2020;110(Suppl 3):S281–S282.33001728
Tan ASL, Hanby EP, Sanders-Jackson A, Lee S, Viswanath K, Potter J. Inequities in tobacco advertising exposure among young adult sexual, racial and ethnic minorities: examining intersectionality of sexual orientation with race and ethnicity. Tobacco Control 2021;30(1):84–93.31857490
Tan ASL, Weinreich E. #PuffBar: how do top videos on TikTok portray Puff Bars? Tobacco Control 2021;30(6): 712–3.32934090
Tangcharoensathien V, Srisookwatana O, Pinprateep P, Posayanonda T, Patcharanarumol W. Multisectoral actions for health: challenges and opportunities in complex policy environments. International Journal of Health Policy Management 2017;6(7):359–63.28812831
Tannenbaum MB, Hepler J, Zimmerman RS, Saul L, Jacobs S, Wilson K, Albarracin D. Appealing to fear: A meta-analysis of fear appeal effectiveness and theories. Psychological Bulletin 2015;141(6):1178–204.26501228
Tattan-Birch H, Brown J, Jackson SE. ‘Give ‘em the vape, sell ‘em the pods’: razor-and-blades methods of pod e-cigarette pricing. Tobacco Control 2022;31(6):773.33766938
Tesler LE, Malone RE. Corporate philanthropy, lobbying, and public health policy. American Journal of Public Health 2008;98(12):2123–33.18923118
Tessman GK, Caraballo RS, Corey CG, Xu X, Chang CM. Exposure to tobacco coupons among U.S. middle and high school students. American Journal of Preventive Medicine 2014;47(2 Suppl 1):S61–S68.25044197
The Center for Black Health & Equity. No menthol Sunday: focus on the victory, go against the grain, 2023; <https://www.nomentholsunday.org/>; accessed: February 15, 2023.
The Lancet. Tobacco control: a Foundation too far? The Lancet 2017;390(10104):1715.
Titus-Ernstoff L, Dalton MA, Adachi-Mejia AM, Longacre MR, Beach ML. Longitudinal study of viewing smoking in movies and initiation of smoking by children. Pediatrics 2008;121(1):15–21.18166552
Tobacco Control Legal Consortium. The Verdict Is In: Findings from United States v. Philip Morris, The Hazards of Smoking. St. Paul (MN): Tobacco Control Legal Consortium, 2006.
Tobacco Tactics. Foundation for a Smoke-Free World, December 15, 2023; <https://tobaccotactics.org/article/foundation-for-a-smoke-free-world/>; accessed: February 22, 2024.
Toomey TL, Chen V, Forster JL, Van Coevering P, Lenk KM. Do cigarette prices vary by brand, neighborhood, and store characteristics? Public Health Reports 2009;124(4):535–40.19618790
Trinkets & Trash. Camel Crush experience: Los dos—tu cigarillo at tu manera [magazine/newspaper advertisement by Camel Crush brand cigarettes], 2013a; <https://trinketsandtrash.org/detail.php?artifactid=7755>; accessed: November 10, 2022.
Trinkets & Trash. Chateau de la Fuerte Birthplace of a Dream” [magazine advertisement by Arturo Fuente cigar brand], 2013b; <https://trinketsandtrash.org/detail.php?artifactid=8822&page=1>; accessed: March 6, 2023.
Trinkets & Trash. Rockin’ boots [email from Marlboro brand cigarettes], 2015; <https://trinketsandtrash.org/detail.php?artifactid=10647>; accessed: November 10, 2022.
Trinkets & Trash. 100% Additive-Free Natural Tobacco [American Spirit ad appearing in Out Magazine in 2016], 2016a; <https://trinketsandtrash.org/detail.php?artifactid=10775&page=1>; accessed: January 18, 2023.
Trinkets & Trash. 100% Additive-Free Natural Tobacco: Try 1 Pack for $2.00 [American Spirit ad appearing in Out magazine in 2016], 2016b; <https://trinketsandtrash.org/detail.php?artifactid=11582&page=1>; accessed: January 18, 2023.
Trinkets & Trash. Just you & blu [magazine advertisement by blu brand e-cigarettes], 2016c; <https://trinketsandtrash.org/detail.php?artifactid=11181>; accessed: November 10, 2022.
Trinkets & Trash. Newport Pleasure! [Newport ad with a couple dancing], 2016d; <https://trinketsandtrash.org/detail.php?artifactid=10905&page=1>; accessed: February 18, 2023.
Trinkets & Trash. Newport pleasure! [Newport menthol ad, Out magazine 2016], 2016e; <https://trinketsandtrash.org/detail.php?artifactid=11117&page=1>; accessed: January 18, 2023.
Trinkets & Trash. Important: less harmful to your wallet [magazine advertisement by blu brand e-cigarettes], 2018a; <https://trinketsandtrash.org/detail.php?artifactid=12632>; accessed: November 10, 2022.
Trinkets & Trash. Ramen for a crowd [email from Newport Lounge], 2018b; <https://trinketsandtrash.org/detail.php?artifactid=14185>; accessed: November 10, 2022.
Trinkets & Trash. We’re proud to call the heartland home [direct mail from Red Seal brand smokeless tobacco], 2018c; <https://trinketsandtrash.org/detail.php?artifactid=13703>; accessed: November 10, 2022.
Trinkets & Trash. $20 challenge: friends night out [email from Newport Lounge], 2019a; <https://trinketsandtrash.org/detail.php?artifactid=14345>; accessed: November 10, 2022.
Trinkets & Trash. Enjoy Black&Mild Blues: Escucha el Playlist de Blues Vibes en Linea [Magazine ad promoting the new Blues concept cigar and a “blues bibes playlist” to stream online], 2019b; <https://trinketsandtrash.org/detail.php?artifactid=15430&page=1>; accessed: February 18, 2023.
Trinkets & Trash. Enjoy taste & aroma [magazine advertisement by Black & Mild brand cigars], 2019c; <https://trinketsandtrash.org/detail.php?artifactid=14198>; accessed: November 10, 2022.
Trinkets & Trash. Marlboro’s latest menthol Smooth Ice now available, 2019d; <https://trinketsandtrash.org/detail.php?artifactid=14583>; accessed: November 10, 2022.
Trinkets & Trash. True Flavor. True Feel. My Blu. [Magazine ad for blu found in Out Magazine in February 2019], 2019e; <https://trinketsandtrash.org/detail.php?artifactid=14217&page=1>; accessed: March 6, 2023.
Trinkets & Trash. Our new inclusion, diversity, & transformation strategy [Instagram post by Swisher Sweets brand cigars], 2020a; <https://trinketsandtrash.org/detail.php?artifactid=15408>; accessed: November 10, 2022.
Trinkets & Trash. Shift Your Enjoyment: Enjoy Black & Mild Filter Tip Cigars [Black & Mild ad found in People (Spanish) in 2020], 2020b; <https://trinketsandtrash.org/detail.php?artifactid=15448&page=1>; accessed: February 18, 2023.
Trinkets & Trash. Copenhagen salutes our soldiers, our veterans, our heroes [magazine advertisement by Copenhagen brand smokeless tobacco], 2021a; <https://trinketsandtrash.org/detail.php?artifactid=15563>; accessed: November 10, 2022.
Trinkets & Trash. Heroes never stop being heroes [online advertisement by VUSE brand e-cigarettes], 2021b; <https://trinketsandtrash.org/detail.php?artifactid=15593>; accessed: November 10, 2022.
Trinkets & Trash. Pass the love [Instagram post by Optimo brand cigars], 2021c; <https://trinketsandtrash.org/detail.php?artifactid=15545>; accessed: November 10, 2022.
Trinkets & Trash. Tell Congress: no tax hikes on nicotine products [email from Camel brand cigarettes], 2021d; <https://trinketsandtrash.org/detail.php?artifactid=15559>; accessed: November 10, 2022.
Trinkets & Trash. You’re invited to the Spirit Circle [email from Natural American Spirit], 2021e; <https://trinketsandtrash.org/detail.php?artifactid=15588>; accessed: November 10, 2022.
Trinkets & Trash. Don’t let them take whats yours [Instagram post by Backwoods Cigars], 2022a; <https://trinketsandtrash.org/detail.php?artifactid=15674>; accessed: November 10, 2022.
Trinkets & Trash. Help stop a menthol ban [email from Marlboro brand cigarettes], 2022b; <https://trinketsandtrash.org/detail.php?artifactid=15658>; accessed: November 10, 2022.
Trinkets & Trash. If you don’t speak out [signage at retail store], 2022c; <https://trinketsandtrash.org/detail.php?artifactid=15719>; accessed: November 10, 2022.
Trinkets & Trash. A Jalisco cowboy’s dream [email about a rewards program from Marlboro brand cigarettes], 2022d; <https://trinketsandtrash.org/detail.php?artifactid=15791>; accessed: December 21, 2022.
Trinkets & Trash. Marlboro rewards: rewards rides on [email from Marlboro brand cigarettes], 2022e; <https://trinketsandtrash.org/detail.php?artifactid=15770>; accessed: November 10, 2022.
Truth Initiative. Vaporized: Youth and young adult exposure to e-cigarette marketing. Washington D.C.: 2015.
Tsai JY, Bluthenthal R, Allem J-P, Garcia R, Garcia J, Unger J, Baezconde-Garbanati L, Sussman SY. Vape shop retailers’ perceptions of their customers, products and services: a content analysis. Tobacco Prevention and Cessation 2016;2(Suppl):3.28736758
Tucker-Seeley RD, Bezold CP, James P, Miller M, Wallington SF. Retail pharmacy policy to end the sale of tobacco products: what is the impact on disparity in neighborhood density of tobacco outlets? Cancer Epidemiology, Biomarkers & Prevention 2016;25(9):1305–10.
Twinamatsiko A. Tobacco Industry Tries, but Fails, to Argue Federal Preemption in Fight to Ban Flavored Products, November 2022; <https://oneill.law.georgetown.edu/wp-content/uploads/2022/11/ONL_Tobacco_Flavor_Ban_P2r1.pdf>; accessed: July 28, 2023.
Tynan MA, Morris D, Weston T. Continued implications of taxing roll-your-own tobacco as pipe tobacco in the U.S.A. Tobacco Control 2015;24(e2):e125–e127.24721968
Tynan MA, Polansky JR, Driscoll D, Garcia C, Glantz SA. Tobacco use in top-grossing movies—United States, 2010–2018. Morbidity and Mortality Weekly Report 2019;68(43):974–8.31671080
U.S. Department of Health and Human Services. Tobacco Use Among U.S. Racial/Ethnic Minority Groups—African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1998.
U.S. Department of Health and Human Services. Reducing Tobacco Use. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2000.
U.S. Department of Health and Human Services. Women and Smoking. A Report of the Surgeon General. Rockville (MD): U.S. Department of Health and Human Services, Public Health Service, Office of the Surgeon General, 2001.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2012a.
U.S. Department of Health and Human Services. A Report of the Surgeon General: Preventing Tobacco Use Among Youth and Young Adults—We CAN Make the Next Generation Tobacco-Free [Consumer Booklet]. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, Office on Smoking and Health, 2012b.
U.S. Department of Health and Human Services. The Health Consequences of Smoking—50 Years of Progress: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2014.
U.S. Department of Health and Human Services. E-Cigarette Use Among Youth and Young Adults. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2016.
U.S. Department of Health and Human Services. Social Media and Youth Mental Health: The U.S. Surgeon General’s Advisory, 2023; <https://www.hhs.gov/sites/default/files/sg-youth-mental-health-social-media-advisory.pdf>; accessed: February 26, 2024.
U.S. Department of Justice. Justice Department announces new initiative to combat redlining [press release], October 22, 2021; <https://www.justice.gov/opa/pr/justice-department-announces-new-initiative-combat-redlining>; accessed: December 21, 2022.
U.S. Food and Drug Administration. FDA commits to evidence-based actions aimed at saving lives and preventing future generations of smokers [press release], April 29, 2021a; <https://www.fda.gov/news-events/press-announcements/fda-commits-evidence-based-actions-aimed-saving-lives-and-preventing-future-generations-smokers>; accessed: June 7, 2021.
U.S. Food and Drug Administration. FDA permits marketing of e-cigarette products, marking first authorization of its kind by the agency [press release], October 12, 2021b; <https://www.fda.gov/news-events/press-announcements/fda-permits-marketing-e-cigarette-products-marking-first-authorization-its-kind-agency>; accessed: May 23, 2022.
U.S. Food and Drug Administration. Preliminary Scientific Evaluation of the Possible Public Health Effects of Menthol Versus Nonmenthol Cigarettes, n.d.; <https://www.fda.gov/media/86497/download>; accessed: November 20, 2023.
U.S. Marketing & Promotions. Kool Mix. February 18, 1998. Brown & Williamson Records Collection; Master Settlement Agreement Collection. Bates No. 241020418–241020422. <https://www.industrydocuments.ucsf.edu/docs/lrfj0081>.
Ulucanlar S, Fooks GJ, Gilmore AB. The policy dystopia model: an interpretive analysis of tobacco industry political activity. PLoS Medicine 2016;13(9):e1002125.27649386
Unger JB, Urman R, Cruz TB, Majmundar A, Barrington-Trimis J, Pentz MA, McConnell R. Talking about tobacco on Twitter is associated with tobacco product use. Preventive Medicine 2018;114:54–6.29898418
United Nations General Assembly. Resolution 66/2, Political Declaration of the High-Level Meeting of the General Assembly on the Prevention and Control of Non-Communicable Diseases (A/RES/66/2), January 24, 2012; <https://digitallibrary.un.org/record/720106?ln=en>; accessed: September 5, 2023.
United States Census Bureau. Glossary [term: census tract], n.d.; <https://www.census.gov/glossary/#term_Censustract>; accessed: December 5, 2019.
United States v. Philip Morris USA Inc., 449 F. Supp. 2d 1 (2006), affirmed in relevant part, 566 F.3d 1095 (D.C. Cir. 2009) (per curiam).
Vakratsas D, Ambler T. How advertising works: what do we really know? Journal of Marketing 1999;63(1):26.
Vape A Vet. About, n.d.; <https://vapeavet.org/about/>; accessed: October 4, 2022.
Venugopal PD, Morse AL, Alrefai-Kirkpatrick R, Tworek C, Chang HW. The co-occurrence of specialty vape shops, social disadvantage, and poor air quality in the United States: an assessment of cumulative risks to youth. Health Equity 2022;6(1):132–41.
Villanti AC, Johnson AL, Ilakkuvan V, Jacobs MA, Graham AL, Rath JM. Social media use and access to digital technology in U.S. young adults in 2016. Journal of Medical Internet Research 2017;19(6):e196.28592394
Villanti AC, Mowery PD, Delnevo CD, Niaura RS, Abrams DB, Giovino GA. Changes in the prevalence and correlates of menthol cigarette use in the U.S.A., 2004–2014. Tobacco Control 2016;25(Suppl 2):ii14–ii20.27729565
Viswanath K. Public communications and its role in reducing and eliminating health disparities. In: Thomson GE, Mitchell F, Williams MB, editors. Examining the Health Disparities Research Plan of the National Institutes of Health: Unfinished Business. Washington (DC): Institute of Medicine, 2006:215–53.
Viswanath K, Kreuter MW. Health disparities, communication inequalities, and eHealth. American Journal of Preventive Medicine 2007;32(5 Suppl):S131–S133.17466818
Vogel EA, Ramo DE, Rubinstein ML, Delucchi KL, Darrow S, Costello C, Prochaska JJ. Effects of social media on adolescents’ willingness and intention to use e-cigarettes: an experimental investigation. Nicotine & Tobacco Research 2021;23(4):694–701.31912147
Vogels EA, Gelles-Watnick R, Massarat N. Teens, Social Media, and Technology 2022. Washington (DC): Pew Research Center, 2022.
Waddell EN, Sacks R, Farley SM, Johns M. Point-of-sale tobacco marketing to youth in New York State. Journal of Adolescent Health 2016;59(3):365–7.
Wagoner KG, Reboussin DM, King JL, Orlan E, Cornacchione Ross J, Sutfin EL. Who is exposed to e-cigarette advertising and where? Differences between adolescents, young adults and older adults. International Journal of Environmental Research and Public Health 2019;16(14):2533.31315189
Wailoo K. Pushing Cool: Big Tobacco, Racial Marketing, and the Untold Story of the Menthol Cigarette. Chicago (IL): University of Chicago Press, 2021.
Walker MW, Navarro MA, Hoffman L, Wagner DE, Stalgaitis CA, Jordan JW. The hip hop peer crowd: an opportunity for intervention to reduce tobacco use among at-risk youth. Addictive Behaviors 2018;82:28–34.29477904
Walley SC, Wilson KM, Winickoff JP, Groner J. A public health crisis: electronic cigarettes, vape, and JUUL. Pediatrics 2019;143(6):e20182741.31122947
Wan N, Siahpush M, Shaikh RA, McCarthy M, Ramos A, Correa A. Point-of-sale e-cigarette advertising among tobacco stores. Journal of Community Health 2017;42(6):1179–86.28488037
Wan N, Siahpush M, Shaikh RA, McCarthy M, Ramos A, Correa A. The association of point-of-sale e-cigarette advertising with socio-demographic characteristics of neighborhoods. Journal of Primary Prevention 2018;39(3):191–203.29564754
Wang TW, Gentzke AS, Creamer MR, Cullen KA, Holder-Hayes E, Sawdey MD, Anic GM, Portnoy DB, Hu S, Homa DM, . Tobacco product use and associated factors among middle and high school students—United States, 2019. Morbidity and Mortality Weekly Report Surveillance Summaries 2019;68(12):1–22.
Wang X, Kim Y, Borowiecki M, Tynan MA, Emery S, King BA. Trends in cigar sales and prices, by product and flavor type—the United States, 2016–2020. Nicotine & Tobacco Research 2022;24(4):606–11.34792585
Ward JB, Gartner DR, Keyes KM, Fliss MD, McClure ES, Robinson WR. How do we assess a racial disparity in health? Distribution, interaction, and interpretation in epidemiological studies. Annals of Epidemiology 2019;29:1–7.30342887
Warner KE. The effects of the anti-smoking campaign on cigarette consumption. American Journal of Public Health 1977;67(7):645–50.879393
Warner KE, Goldenhar LM, McLaughlin CG. Cigarette advertising and magazine coverage of the hazards of smoking. A statistical analysis. New England Journal of Medicine 1992;326(5):305–9.1728734
Wheeler DC, Do EK, Hayes RB, Fugate-Laus K, Fallavollita WL, Hughes C, Fuemmeler BF. Neighborhood disadvantage and tobacco retail outlet and vape shop outlet rates. International Journal of Environmental Research and Public Health 2020;17(8):2864.32326297
Widome R, Brock B, Klein EG, Forster JL. Smokeless tobacco advertising at the point of sale: prevalence, placement, and demographic correlates. Nicotine & Tobacco Research 2012;14(2):217–23.22080586
Widome R, Brock B, Noble P, Forster JL. The relationship of neighborhood demographic characteristics to point-of-sale tobacco advertising and marketing. Ethnicity & Health 2013;18(2):136–51.22789035
Wilkinson AV, Spitz MR, Prokhorov AV, Bondy ML, Shete S, Sargent JD. Exposure to smoking imagery in the movies and experimenting with cigarettes among Mexican heritage youth. Cancer Epidemiology, Biomarkers & Prevention 2009;18(12):3435–43.
Wojdynski BW, Evans NJ. Going native: effects of disclosure position and language on the recognition and evaluation of online native advertising. Journal of Advertising 2015;45(2):157–68.
World Health Organization. Tobacco Industry and Corporate Responsibility … An Inherent Contradiction, 2003; <https://escholarship.org/uc/item/6kf7q7v9>; accessed: November 8, 2023.
World Health Organization. WHO Statement on Philip Morris funded Foundation for a Smoke-Free World, 2017; <https://www.who.int/news/item/28-09-2017-who-statement-on-philip-morris-funded-foundation-for-a-smoke-free-world>; accessed: June 7, 2021.
Xie Z, Wang X, Gu Y, Li D. Exploratory analysis of electronic cigarette-related videos on YouTube: observational study. Interactive Journal of Medical Research 2021;10(3):e27302.34255663
Yach D. Foundation for a smoke-free world. Lancet 2017; 390(10104):1807–10.29047446
Yang Q, Liu J, Lochbuehler K, Hornik R. Does seeking e-cigarette information lead to vaping? Evidence from a national longitudinal survey of youth and young adults. Health Communication 2019;34(3):298–305.29236549
Yerger V. What more evidence is needed? Remove menthol cigarettes from the marketplace-now. Tobacco Control 2022;31(4):493–4.34535506
Yerger VB, Malone RE. African American leadership groups: smoking with the enemy. Tobacco Control 2002;11(4):336–45.12432159
Yerger VB, Przewoznik J, Malone RE. Racialized geography, corporate activity, and health disparities: tobacco industry targeting of inner cities. Journal of Health Care for the Poor and Underserved 2007;18(4 Suppl):10–38.18065850
Young-Wolff KC, Henriksen L, Delucchi K, Prochaska JJ. Tobacco retailer proximity and density and nicotine dependence among smokers with serious mental illness. American Journal of Public Health 2014;104(8):1454–63.24922145
Yu D, Peterson NA, Sheffer MA, Reid RJ, Schnieder JE. Tobacco outlet density and demographics: analysing the relationships with a spatial regression approach. Public Health 2010;124(7):412–6.20541232
Zhu S-H, Gamst A, Lee M, Cummins S, Yin L, Zoref L. The use and perception of electronic cigarettes and snus among the U.S. population. PLoS One 2013;8(10): e79332.24250756

## Chapter 5 Appendix

### Appendix 5.1 Search Terms Used for Chapter 5

Table 5A.1 Search terms used for Chapter 5

Topic | Search terms
Tobacco industry influence
Retail (Indexes: PubMed and Web of Science Core Collection) | PubMed:; ((tobacco[Title] OR cigarettes[Title] OR cigarette[Title] OR smoking[Title] OR cigar[Title] OR cigarillo[Title] OR smoking[Title] OR “tobacco industry”[Title] OR hookah[Title] OR snus[Title]) AND (ethnic[Title/Abstract] OR disparity[Title/Abstract] OR disparities[Title/Abstract] OR inequality[Title/Abstract] OR disadvantage[Title/Abstract] OR race[Title/Abstract] OR racial[Title/Abstract] OR minority[Title/Abstract] OR “African American”[Title/Abstract] OR “African-American”[Title/Abstract] OR “African”[Title/Abstract] OR black[Title/Abstract] OR Latino[Title/Abstract] OR Hispanic[Title/Abstract] OR Asian[Title/Abstract] OR “Native American”[Title/Abstract] OR “Alaska Native”[Title/Abstract] OR “Pacific Islander”[Title/Abstract] OR economic[Title/Abstract] OR socioeconomic[Title/Abstract] OR SES[Title/Abstract] OR low-income[Title/Abstract] OR poverty[Title/Abstract] OR gay[Title/Abstract] OR lesbian[Title/Abstract] OR bisexual[Title/Abstract] OR transgender[Title/Abstract] OR homosexual[Title/Abstract] OR LGBT[Title/Abstract] OR homeless[Title/Abstract] OR mentally ill[Title/Abstract] OR substance use[Title/Abstract] OR geographic[Title/Abstract] OR rural[Title/Abstract] OR occupation[Title/Abstract])) AND (retail[Title] OR shop[Title] OR retailer[Title] OR retailers[Title] OR pharmacy[Title] OR supermarket[Title] OR grocer[Title] OR grocery[Title] OR vendor[Title] OR supermarket[Title] OR “gas station”[Title] OR outlet[Title] OR price[Title] OR density[Title] OR marketing[Title] OR advertising[Title] OR ad[Title] OR ads[Title] OR promotion[Title] OR placement[Title] OR signs[Title] OR discount[Title] OR display[Title] OR “point of sale”[Title] OR “point-of-sale”[Title] OR “residence characteristics”[Title] OR neighborhood[Title] OR targeting[Title]); Web of Science Core Collection:; TITLE: (tobacco OR cigarettes OR cigarette OR smoking OR cigar OR cigarillo OR smoking OR “tobacco industry” OR hookah OR snus) AND TITLE: (ethnic OR disparity OR disparities OR inequality OR disadvantage OR race OR racial OR minority OR African American OR African-American OR African OR black OR Latino OR Hispanic OR Asian OR Native American OR Alaska Native OR Pacific Islander OR economic OR socioeconomic OR SES OR low-income OR poverty OR gay OR lesbian OR bisexual OR transgender OR homosexual OR LGBT OR homeless OR mentally ill OR substance use OR geographic OR rural OR occupation) AND TITLE: (retail OR shop OR retailer OR retailers OR pharmacy OR supermarket OR grocer OR grocery OR vendor OR supermarket OR gas station OR outlet OR price OR density OR marketing OR advertising OR ad OR ads OR promotion OR placement OR signs OR discount OR display OR point of sale OR point-of-sale OR residence characteristics OR neighborhood OR targeting); Refined by: [excluding] DOCUMENT TYPES: (MEETING ABSTRACT) AND LANGUAGES: (ENGLISH); Timespan: 2008–2018. Indexes: SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC
Marketing and media (Index: PubMed) | Search #1:; (tobacco[ti] OR cigarette*[ti] OR smoking[ti] OR smoker*[ti] OR nicotine[ti] OR juul[ti] OR cigar*[ti] OR cigarillo*[ti] OR snus[ti] OR smokeless[ti] OR heat-not-burn[ti] OR hookah[ti] OR waterpipe[ti] OR secondhand smoke[ti] OR second-hand smoke[ti]) AND (disparity[tw] OR disparities[tw] OR inequalit*[tw] OR equity[tw] OR inequit*[tw]) (race[tw] OR racial*[tw] OR ethnic*[tw] OR black*[tw] OR African American*[ti] OR Asian American*[ti] OR minority[tw] OR minorities[tw] OR Hispanic*[ti] OR Mexican American*[ti] OR Latino*[ti] OR Latina*[ti] OR underserved[tw] OR underprivileged[tw] OR urban[tw] OR rural[tw] OR geographic*[ti] OR demographic*[ti] OR sex*[ti] OR gender[ti] OR homosexual*[tw] OR lesbian*[tw] OR bisexual[tw] OR lgbt*[ tw] OR age[ti] OR youth*[ti] OR teen*[ti] OR elderly[ti] OR mentally ill*[ti] OR mental health[ti] OR disabled[ti] OR transgender*[ti] OR social class[ti] OR socio-economic*[ti] OR socioeconomic*[ti] OR income[ti] OR poverty[ti] OR poor[ti] OR occupation*[ti] OR military[ti] OR veteran*[ti] OR education*[ti]) AND (social media OR social networking site*[tw] OR social networking[tw] OR Twitter[tw] OR Instagram[tw] OR Facebook[tw] OR Reddit[tw] OR social marketing OR influencer marketing OR digital media[tw] OR digital marketing[tw]); Sort by: Publication Date Filters: Abstract; Publication date from 2008/01/01; English; Search #2:; Add Search (tobacco[ti] OR cigarette*[ti] OR smoking[ti] OR smoker*[ti] OR nicotine[ti] OR juul[ti] OR cigar*[ti] OR cigarillo*[ti] OR snus[ti] OR smokeless[ti] OR heat-not-burn[ti] OR hookah[ti] OR waterpipe[ti] OR secondhand smoke[ti] OR second-hand smoke[ti]) AND (social media[tw] OR social networking site*[tw] OR social networking[tw] OR Twitter[tw] OR Instagram[tw] OR Facebook[tw] OR Reddit[tw] OR social marketing OR influencer marketing OR digital media[tw] OR digital marketing[tw]); Sort by: Publication Date Filters: Abstract; Publication date from 2018/01/01; English
E-cigarettes and emerging tobacco products (Indexes: Google Scholar, Ovid, and PsycInfo) | (“LGBT” OR “rural” OR “SES” OR “psychiatric” OR “homeless” OR “minority” OR “age”); AND; (“e-cigarette,” “JUUL,” “pod mod,” “heat not burn,” and “heated tobacco product”, “nicotine pouch”, “modern oral nicotine”, “tobacco-free nicotine”)
Tobacco industry response: Political (Indexes: PubMed and Web of Science) | PubMed:; (((tobacco[Title/Abstract] OR cigarettes[Title/Abstract] OR cigarette[Title/Abstract] OR smoking[Title/Abstract]) AND (company[Title/Abstract] OR companies[Title/Abstract] OR industry[Title/Abstract] OR industries[Title/Abstract] OR corporate[Title/Abstract] OR corporation[Title/Abstract] OR (business[Title/Abstract] OR business’[Title/Abstract] OR business’s[Title/Abstract] OR business’wo[Title/Abstract] OR businesscase[Title/Abstract] OR businesse[Title/Abstract] OR businesses[Title/Abstract] OR businesses’[Title/Abstract] OR businessess[Title/Abstract] OR businessess’[Title/Abstract] OR businessification[Title/Abstract] OR businessification’[Title/Abstract] OR businessization[Title/Abstract] OR businesslike[Title/Abstract] OR businessman[Title/Abstract] OR businessman’s[Title/Abstract] OR businessmen[Title/Abstract] OR businessmen’s[Title/Abstract] OR businessobjects[Title/Abstract] OR businesspeak[Title/Abstract] OR businesspeo[Title/Abstract] OR businesspeople[Title/Abstract] OR businessperson[Title/Abstract] OR businesspersons[Title/Abstract] OR businesssource[Title/Abstract] OR businesssourcecomplete[Title/Abstract] OR businesstrade[Title/Abstract] OR businessweek[Title/Abstract] OR businessweek’s[Title/Abstract] OR businesswide[Title/Abstract] OR businesswoman[Title/Abstract] OR businesswomen[Title/Abstract]))) AND (ethnic[Title/Abstract] OR disparity[Title/Abstract] OR disparities[Title/Abstract] OR inequality[Title/Abstract] OR disadvantage[Title/Abstract] OR race[Title/Abstract] OR racial[Title/Abstract] OR minority[Title/Abstract] OR “African American”[Title/Abstract] OR “African-American”[Title/Abstract] OR “African”[Title/Abstract] OR black[Title/Abstract] OR Latino[Title/Abstract] OR Hispanic[Title/Abstract] OR Asian[Title/Abstract] OR “Native American”[Title/Abstract] OR “Alaska Native”[Title/Abstract] OR “Pacific Islander”[Title/Abstract] OR economic[Title/Abstract] OR socioeconomic[Title/Abstract] OR SES[Title/Abstract] OR low-income[Title/Abstract] OR poverty[Title/Abstract] OR gay[Title/Abstract] OR lesbian[Title/Abstract] OR bisexual[Title/Abstract] OR transgender[Title/Abstract] OR homosexual[Title/Abstract] OR LGBT[Title/Abstract] OR homeless[Title/Abstract] OR mentally ill[Title/Abstract] OR substance use[Title/Abstract] OR geographic[Title/Abstract] OR rural[Title/Abstract] OR occupation[Title/Abstract])) AND (political[Title/Abstract] OR politics[Title/Abstract] OR “political party”[Title/Abstract] OR legislator[Title/Abstract] OR senate[Title/Abstract] OR congress[Title/Abstract] OR representative[Title/Abstract] OR litigation[Title/Abstract] OR ballot[Title/Abstract] OR lobby[Title/Abstract] OR pre-emption[Title/Abstract] OR front group[Title/Abstract] OR election[Title/Abstract] OR ally[Title/Abstract] OR allies[Title/Abstract]); Web of Science:; TITLE: (tobacco OR cigarettes OR cigarette OR smoking) AND TITLE: (company OR companies OR industry OR industries OR corporate OR corporation OR business*) AND TOPIC: (ethnic OR disparity OR disparities OR inequality OR disadvantage OR race OR racial OR minority OR African American OR African-American OR African OR black OR Latino OR Hispanic OR Asian OR Native American OR Alaska Native OR Pacific Islander OR economic OR socioeconomic OR SES OR low-income OR poverty OR gay OR lesbian OR bisexual OR transgender OR homosexual OR LGBT OR homeless OR mentally ill OR substance use OR geographic OR rural OR occupation) AND TOPIC: (political OR politics OR political party or legislator OR senate OR congress OR representative OR litigation OR ballot OR lobby OR pre-emption OR front group OR election OR ally OR allies); Refined by: LANGUAGES: (ENGLISH); Timespan: 2008–2018. Indexes: SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC
Tobacco industry response: Economic (Indexes: PubMed and Web of Science) | PubMed:; (((tobacco[Title/Abstract] OR cigarettes[Title/Abstract] OR cigarette[Title/Abstract] OR smoking[Title/Abstract]) AND (company[Title/Abstract] OR companies[Title/Abstract] OR industry[Title/Abstract] OR industries[Title/Abstract] OR corporate[Title/Abstract] OR corporation[Title/Abstract] OR (business[Title/Abstract] OR business’[Title/Abstract] OR business’s[Title/Abstract] OR business’wo[Title/Abstract] OR businesscase[Title/Abstract] OR businesse[Title/Abstract] OR businesses[Title/Abstract] OR businesses’[Title/Abstract] OR businessess[Title/Abstract] OR businessess’[Title/Abstract] OR businessification[Title/Abstract] OR businessification’[Title/Abstract] OR businessization[Title/Abstract] OR businesslike[Title/Abstract] OR businessman[Title/Abstract] OR businessman’s[Title/Abstract] OR businessmen[Title/Abstract] OR businessmen’s[Title/Abstract] OR businessobjects[Title/Abstract] OR businesspeak[Title/Abstract] OR businesspeo[Title/Abstract] OR businesspeople[Title/Abstract] OR businessperson[Title/Abstract] OR businesspersons[Title/Abstract] OR businesssource[Title/Abstract] OR businesssourcecomplete[Title/Abstract] OR businesstrade[Title/Abstract] OR businessweek[Title/Abstract] OR businessweek’s[Title/Abstract] OR businesswide[Title/Abstract] OR businesswoman[Title/Abstract] OR businesswomen[Title/Abstract]))) AND (ethnic[Title/Abstract] OR disparity[Title/Abstract] OR disparities[Title/Abstract] OR inequality[Title/Abstract] OR disadvantage[Title/Abstract] OR race[Title/Abstract] OR racial[Title/Abstract] OR minority[Title/Abstract] OR “African American”[Title/Abstract] OR “African-American”[Title/Abstract] OR “African”[Title/Abstract] OR black[Title/Abstract] OR Latino[Title/Abstract] OR Hispanic[Title/Abstract] OR Asian[Title/Abstract] OR “Native American”[Title/Abstract] OR “Alaska Native”[Title/Abstract] OR “Pacific Islander”[Title/Abstract] OR economic[Title/Abstract] OR socioeconomic[Title/Abstract] OR SES[Title/Abstract] OR low-income[Title/Abstract] OR poverty[Title/Abstract] OR gay[Title/Abstract] OR lesbian[Title/Abstract] OR bisexual[Title/Abstract] OR transgender[Title/Abstract] OR homosexual[Title/Abstract] OR LGBT[Title/Abstract] OR homeless[Title/Abstract] OR mentally ill[Title/Abstract] OR substance use[Title/Abstract] OR geographic[Title/Abstract] OR rural[Title/Abstract] OR occupation[Title/Abstract])) AND (price[Title/Abstract] OR tax[Title/Abstract] OR promotion[Title/Abstract] OR discount[Title/Abstract] OR labeling[Title/Abstract] OR coupon[Title/Abstract] OR packaging[Title/Abstract]); ((tobacco[Title/Abstract] OR cigarettes[Title/Abstract] OR cigarette[Title/Abstract] OR smoking[Title/Abstract]) AND (company[Title/Abstract] OR companies[Title/Abstract] OR industry[Title/Abstract] OR industries[Title/Abstract] OR corporate[Title/Abstract] OR corporation[Title/Abstract] OR (business[Title/Abstract] OR business’[Title/Abstract] OR business’s[Title/Abstract] OR business’wo[Title/Abstract] OR businesscase[Title/Abstract] OR businesse[Title/Abstract] OR businesses[Title/Abstract] OR businesses’[Title/Abstract] OR businessess[Title/Abstract] OR businessess’[Title/Abstract] OR businessification[Title/Abstract] OR businessification’[Title/Abstract] OR businessization[Title/Abstract] OR businesslike[Title/Abstract] OR businessman[Title/Abstract] OR businessman’s[Title/Abstract] OR businessmen[Title/Abstract] OR businessmen’s[Title/Abstract] OR businessobjects[Title/Abstract] OR businesspeak[Title/Abstract] OR businesspeo[Title/Abstract] OR businesspeople[Title/Abstract] OR businessperson[Title/Abstract] OR businesspersons[Title/Abstract] OR businesssource[Title/Abstract] OR businesssourcecomplete[Title/Abstract] OR businesstrade[Title/Abstract] OR businessweek[Title/Abstract] OR businessweek’s[Title/Abstract] OR businesswide[Title/Abstract] OR businesswoman[Title/Abstract] OR businesswomen[Title/Abstract]))) AND (over-shifting[Title/Abstract] OR over-shift[Title/Abstract] OR over-shifted[Title/Abstract]); Web of Science:; TITLE: (tobacco OR cigarettes OR cigarette OR smoking) AND TITLE: (company OR companies OR industry OR industries OR corporate OR corporation OR business*) AND TOPIC: (ethnic OR disparity OR disparities OR inequality OR disadvantage OR race OR racial OR minority OR “African American” OR “African-American” OR “African” OR black OR Latino OR Hispanic OR Asian OR “Native American” OR “Alaska Native” OR “Pacific Islander” OR economic OR socioeconomic OR SES OR low-income OR poverty OR gay OR lesbian OR bisexual OR transgender OR homosexual OR LGBT OR homeless OR mentally ill OR substance use OR geographic OR rural OR occupation) AND TOPIC: (price OR tax OR promotion OR discount OR labeling OR coupon OR packaging); Timespan: 2008–2018. Indexes: SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC.; TITLE: (tobacco OR cigarettes OR cigarette OR smoking) AND TITLE: (company OR companies OR industry OR industries OR corporate OR corporation OR business*) AND TOPIC: (over-shifting OR over-shift OR over-shifted); Timespan: 2008–2018. Indexes: SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC
Tobacco industry response: Corporate social responsibility and community (Indexes: PubMed and Web of Science) | PubMed:; (((tobacco[Title/Abstract] OR cigarettes[Title/Abstract] OR cigarette[Title/Abstract] OR smoking[Title/Abstract]) AND (company[Title/Abstract] OR companies[Title/Abstract] OR industry[Title/Abstract] OR industries[Title/Abstract] OR corporate[Title/Abstract] OR corporation[Title/Abstract] OR (business[Title/Abstract] OR business’[Title/Abstract] OR business’s[Title/Abstract] OR business’wo[Title/Abstract] OR businesscase[Title/Abstract] OR businesse[Title/Abstract] OR businesses[Title/Abstract] OR businesses’[Title/Abstract] OR businessess[Title/Abstract] OR businessess’[Title/Abstract] OR businessification[Title/Abstract] OR businessification’[Title/Abstract] OR businessization[Title/Abstract] OR businesslike[Title/Abstract] OR businessman[Title/Abstract] OR businessman’s[Title/Abstract] OR businessmen[Title/Abstract] OR businessmen’s[Title/Abstract] OR businessobjects[Title/Abstract] OR businesspeak[Title/Abstract] OR businesspeo[Title/Abstract] OR businesspeople[Title/Abstract] OR businessperson[Title/Abstract] OR businesspersons[Title/Abstract] OR businesssource[Title/Abstract] OR businesssourcecomplete[Title/Abstract] OR businesstrade[Title/Abstract] OR businessweek[Title/Abstract] OR businessweek’s[Title/Abstract] OR businesswide[Title/Abstract] OR businesswoman[Title/Abstract] OR businesswomen[Title/Abstract]))); AND (ethnic[Title/Abstract] OR disparity[Title/Abstract] OR disparities[Title/Abstract] OR inequality[Title/Abstract] OR disadvantage[Title/Abstract] OR race[Title/Abstract] OR racial[Title/Abstract] OR minority[Title/Abstract] OR “African American”[Title/Abstract] OR “African-American”[Title/Abstract] OR “African”[Title/Abstract] OR black[Title/Abstract] OR Latino[Title/Abstract] OR Hispanic[Title/Abstract] OR Asian[Title/Abstract] OR “Native American”[Title/Abstract] OR “Alaska Native”[Title/Abstract] OR “Pacific Islander”[Title/Abstract] OR economic[Title/Abstract] OR socioeconomic[Title/Abstract] OR SES[Title/Abstract] OR low-income[Title/Abstract] OR poverty[Title/Abstract] OR gay[Title/Abstract] OR lesbian[Title/Abstract] OR bisexual[Title/Abstract] OR transgender[Title/Abstract] OR homosexual[Title/Abstract] OR LGBT[Title/Abstract] OR homeless[Title/Abstract] OR mentally ill[Title/Abstract] OR substance use[Title/Abstract] OR geographic[Title/Abstract] OR rural[Title/Abstract] OR occupation[Title/Abstract])) AND (social[Title/Abstract] OR responsibility[Title/Abstract] OR community[Title/Abstract] OR communities[Title/Abstract] OR philanthropy[Title/Abstract] OR “public relations”[Title/Abstract] OR funding[Title/Abstract] OR education[Title/Abstract] OR festival[Title/Abstract] OR music[Title/Abstract] OR sponsor[Title/Abstract] OR sport[Title/Abstract] OR event[Title/Abstract] OR marketing[Title/Abstract] OR advertising[Title/Abstract] OR advocacy[Title/Abstract] OR contribution[Title/Abstract] OR gift[Title/Abstract]); Web of Science:; TITLE: (tobacco OR cigarettes OR cigarette OR smoking) AND TITLE: (company OR companies OR industry OR industries OR corporate OR corporation OR business*) AND TOPIC: (ethnic OR disparity OR disparities OR inequality OR disadvantage OR race OR racial OR minority OR African American OR African-American OR African OR black OR Latino OR Hispanic OR Asian OR Native American OR Alaska Native OR Pacific Islander OR economic OR socioeconomic OR SES OR low-income OR poverty OR gay OR lesbian OR bisexual OR transgender OR homosexual OR LGBT OR homeless OR mentally ill OR substance use OR geographic OR rural OR occupation) AND TOPIC: (social OR responsibility OR community OR communities OR philanthropy OR “public relations” OR funding OR education OR festival OR music OR sponsor OR sport OR event OR marketing OR advertising OR advocacy OR contribution OR gift); Refined by: LANGUAGES: ( ENGLISH ); Timespan: 2008–2018. Indexes: SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC

1 The Consolidated Appropriations Act of 2022 (2022), enacted on March 15, 2022, amended the definition of the term tobacco product in section 201(rr) of the Federal Food, Drug & Cosmetic Act to include products that contain nicotine from any source.

2 For historic context and a broader view of the tobacco industry’s role and tactics in shaping tobacco use patterns, the tobacco market-place, and the broader environment, see the judicial decision in United States v. Philip Morris USA Inc. (2009) and the review by Tobacco Control Legal Consortium (2006)