# Chapter 4 Social and Environmental Influences on Tobacco-Related Health Disparities

## Introduction

This chapter describes the evidence for many of the multifaceted influences on tobacco-related health disparities that go beyond individual factors. The evidence draws heavily on a socioecological model that situates individual behaviors within a multilevel framework of interpersonal, community, or neighborhood environments and larger societal and policy contexts (McLeroy et al. 1988). It also draws on the premise that individual tobacco use is heavily influenced by the social determinants of health: “conditions in the environments in which people are born, live, learn, work, play, worship and age, that affect a wide range of health, function and quality-of-life outcomes and risks” (Office of Disease Prevention and Health Promotion n.d.). Accordingly, this chapter builds on the following conclusion from the 1998 Surgeon General’s report:

“No single factor determines patterns of tobacco use among racial/ethnic minority groups; these patterns are the result of complex interactions of multiple factors, such as socioeconomic status [SES], cultural characteristics, acculturation, stress, biological elements, targeted advertising, price of tobacco products, and varying capacities of communities to mount effective tobacco control initiatives” (U.S. Department of Health and Human Services [USDHHS] 1998, p. 6).

This chapter goes beyond diverse racial and ethnic populations to examine the social and environmental factors that influence tobacco-related health disparities among a broader set of population groups, including sexual orientation and gender identity groups and socioeconomically disadvantaged populations. The chapter also examines social and environmental influences on tobacco-related health disparities by age, sex, geographic location, and occupation as data are available.

Figure 4.1 provides a causal loop diagram (CLD) and theoretical model that visualizes the complex, interconnected structural, environmental, individual, and root causes of smoking that lead to tobacco-related health disparities (Mills et al. 2023). This model developed by Mills and colleagues (2023)—based on existing conceptual and empirical theories of smoking, social stress theories, and fundamental cause theory—was revised with feedback from researchers and tobacco control stakeholders (Link and Phelan 1995; Phelan et al. 2010; Phelan and Link 2015). The CLD model is intended to identify variables that are positively or negatively correlated with smoking (or quitting) and generate hypotheses of both intended and unintended consequences of interventions as they pertain to tobacco-related behavioral outcomes (Mills et al. 2023).

This chapter, together with Chapter 5, builds on this CLD model (Figure 4.1) to show that these nested systems—the social, environmental, and commercial influences including those from the tobacco industry—are complex and interrelated. Early life experiences and chronic stressors, such as discrimination, can influence the tobacco use continuum, including initiation; current use and the frequency and intensity of use; quitting and relapse; exposure to secondhand tobacco smoke; and ultimately, morbidity and mortality. Social, environmental, and tobacco industry influences can affect patterns of tobacco product use over time at the individual level and at the societal level.

Leveraging the CLD model, this chapter reviews the scientific literature published between 2008 and 2021 on how social and environmental factors influence tobacco use among diverse populations (Box 4.1). While addressing a wider variety of tobacco products than cigarettes, this chapter seeks to add to but not duplicate evidence published in National Cancer Institute (NCI) Tobacco Control Monograph 22, which included related searches of literature typically published between 2000 and 2011 (NCI 2017b). This chapter includes scientific findings from systematic literature reviews conducted before 2008 to provide context and understanding of historical trends in effects between social influences and tobacco-related health disparities.

Box 4.1 Social and environmental influences on disparities in tobacco product use explored in this chapter

Social influences:; - Family and peer influences and their interactions; - Religion; - Discrimination; - Acculturation | Environmental influences:; - Home; - School; - Work environments; - Healthcare

Figure 4.1 shows how social factors, environmental influences, and activities of the tobacco industry combine to influence smoking and individual risk of tobacco-related health disparities. To the extent possible, this chapter focuses on how various influences may contribute to the generation or persistence of tobacco-related health disparities rather than simply on how each factor may influence tobacco use in general. Where possible, this chapter focuses on systematic literature reviews of studies that compare demographic groups within the U.S. context or examine differences within population groups experiencing tobacco-related health disparities. Chapter 7 more fully addresses the impact of interventions and policies on tobacco-related health disparities.

Figure 4.1 Causal loop diagram that links structural, environmental, and individual causes of racial and ethnic and socioeconomic disparities in smoking

This figure depicts a causal loop diagram linking individual, environmental, and structural causes of disparities in smoking. Individual factors include sense of control, stress/anxiety, cravings/addiction, menthol preference, and perceptions of tobacco use as low risk. Environmental factors include zoning laws, tobacco prices, smokefree homes/workplaces, normalization of smoking, product and flavor availability, tobacco use among family and friends, and tobacco companies’ profit maximization efforts. Root causes or fundamental factors include structural racism, marginalization, low-wage work, health care access, segregation, social capital, housing instability, financial strain, discrimination, and tobacco retailer density/proximity. A combination of environmental factors, root causes, and fundamental factors includes access to culturally relevant cessation services and targeted tobacco marketing. Variables move in either the same direction (as indicated by an addition symbol) or the opposite direction (as indicated by a subtraction symbol).

Source: Figure 2 in Mills and colleagues (2023); adapted with permission.

## Social Influences

Social influences on tobacco use include interpersonal influences, such as peers, family members, and other members of a person’s social network; religious and cultural influences, which inform acculturation status and ethnic identity; and adverse interpersonal influences, such as experiences with discrimination. The 2012 Surgeon General’s report, Preventing Tobacco Use Among Youth and Young Adults, identified social influences as “among the most robust and consistent predictors of adolescent smoking” (USDHHS 2012, p. 563). The studies in this section were examined to determine whether the strength of the association between particular social influences and tobacco product use or tobacco-related health disparities varies across other demographic groups beyond adolescents.

### Literature Review Methods

Studies reviewed for this section were initially identified in 2018 and updated in December 2021 through a literature search of several databases, including PubMed, ABI Inform, EBSCO, PsycINFO, and Web of Science. Specific search terms are listed in Table A4.1 (Appendix 4.1). The search was restricted to peer-reviewed empirical studies that were published in the English language between 2008 and December 2021. The search prioritized systematic reviews but also included relevant peer-reviewed studies not in reviews (e.g., findings from randomized controlled trials). Studies were excluded if they did not address a tobacco-related disparity (e.g., prevalence of tobacco use, tobacco-related morbidity or mortality that occurs at a disproportionately higher rate in a social or demographic group in the United States) in their examination of the association between social influence and tobacco use. Articles that included only the “main effect” of a related social influence on tobacco use not focused on a disparity group were generally excluded, as were non-U.S. studies. Included articles were divided into six categories: family and peers; religion and culture; discrimination; acculturation; ethnic identity; and trauma, violence, or adverse childhood events.

### Family and Peer Influences

Social influences from family and peers are associated with tobacco product use (Hoffman et al. 2006; Simons-Morton and Farhat 2010; Cengelli et al. 2012; Seo and Huang 2012; Agaku et al. 2013; Wellman et al. 2016; Perikleous et al. 2018). In the CLD model (Figure 4.1), tobacco use among family and friends reinforces the normalization of smoking and perception of tobacco use as low risk, which encourages smoking behavior among other family and friends. Several studies have examined whether the effects of family and peer characteristics on tobacco use differ between specific groups of populations to a greater or lesser extent than among other population groups.

#### Family Influences

Studies of family influences on tobacco use focus on family members’ smoking behaviors and characteristics of the parent–adolescent relationship, including parenting behaviors. This section is organized according to these types of family influences. More specifically, this section breaks down the comparative analytic procedures that are used to determine associations between sociodemographic characteristics and tobacco-related health disparities (e.g., race and ethnicity, SES, sex/sexual orientation and gender identity, or age). Parental smoking has been shown to predict adolescent smoking in longitudinal studies (Vuolo and Staff 2013; Vandewater et al. 2014). In a study examining associations between parent and adolescent smoking, Kandel and colleagues (2015) used 2004–2012 data from the National Survey on Drug Use and Health (also see Appendix 2.1, Chapter 2) to compare intergenerational patterns of lifetime smoking and nicotine dependence among a sample of 35,000 parent–adolescent dyads. Current smoking by parents was found to be a risk factor for adolescent lifetime smoking regardless of the level of parental nicotine dependence, and this association did not differ by race or ethnicity. However, White youth and their parents were more likely to smoke and have nicotine dependence than African American or Hispanic youth and their parents (Kandel et al. 2015).

Studies have investigated the effect of parental psychosocial factors on adolescent smoking behaviors. For example, Mahabee-Gittens and colleagues (2012) assessed the association between various parenting behaviors and cigarette smoking among 6,426 African American, Hispanic, or White adolescents in the National Survey of Parents and Youth, a longitudinal, nationally representative household survey of parent–adolescent dyads. The study analyzed data from 7,620 youth who were interviewed in Round 1 of the study; data were collected from November 1999 through June 2001. Parenting factors included family influences—which grouped together connectedness, shared activities, parental monitoring, intention to monitor, attitudes toward monitoring, and antismoking communication—and parental punishment. After controlling for various individual (e.g., age, gender, peer smoking) and parent–family (e.g., parent education, parent smoking status, family income, family structure) covariates, higher levels of family influences and parental punishment were protective against ever and recent smoking among youth in all three racial and ethnic groups. However, all adjusted odds ratios (ORs) reflected relatively small effects.

In a similar study, Bohnert and colleagues (2009) used a representative sample of 572 Black and White children from a large Midwest metropolitan region to examine racial differences in the association between parental monitoring and adolescent smoking initiation. This longitudinal study found that close parental monitoring of 11-year-old children predicted a reduced likelihood of smoking initiation when those children reached 17 years of age; this effect was seen among White children but not among Black children. The authors found no evidence that parental monitoring influenced escalation to daily smoking among Black or White youth who had experimented with smoking. These findings align with previous studies suggesting a greater protective effect of parental monitoring in White youth than in Black youth (Griesler et al. 2002; Nowlin and Colder 2007; Ramchand et al. 2007).

Stanton and colleagues (2014) surveyed 459 eighth graders from Hispanic, African American, White, and mixed ethnic backgrounds to determine the association between smoking among youth and authoritative parenting styles and parental communication that includes antitobacco communication (things parents do or say to reduce the likelihood of their child using tobacco). Parental antitobacco communication was inversely associated with smoking overall, as youth were less likely to use tobacco if their parents discouraged such use. This association did not vary by race and ethnicity, even though the study design allowed for testing hypothesized differences in effects by racial and ethnic group. The authors speculated that an authoritative parenting style might reduce tobacco use in youth across racial and ethnic groups. Future research could clarify this mechanism for racial and ethnic groups.

Elsewhere, Gutman and colleagues (2011) compared cigarette smoking among 1,102 African American families and White families by examining the trajectories of cigarette use in 13- to 19-year-old adolescents. Their longitudinal study focused on shared parent–adolescent decision making, negative family interactions, and identification with parents. Family relations differentially affected cigarette use depending on race and sex. Shared parent–child decision making appeared to decrease cigarette smoking among boys but increase smoking among girls. The association between negative family interactions and cigarette smoking was stronger among African American boys than among White boys but was stronger among White girls than among African American girls.

An analysis of data from the 2002–2003 National Latino and Asian American Study examined the relationship between different dimensions of social capital and the prevalence of smoking among 998 Chinese, Filipino, and Vietnamese American men (Li and Delva 2012). Social capital was measured by self-report and included family and friend connections, neighborhood and family cohesion, and family conflict. For Asian American men overall in the study, neighborhood cohesion was inversely related to smoking, but the other social capital variables were not. In an analysis stratified by Asian ethnic group, neighborhood cohesion was significantly inversely associated with smoking only among Vietnamese American men; the direction of the association for the other Asian ethnic subgroups was similar. Further, family cohesion was associated with increased odds of smoking among Filipino American men. The authors speculated that neighborhood social norms might have protective effects against smoking for Vietnamese men and that traditional Filipino family values may influence positive attitudes toward smoking for men. It is important to note that similar gendered family values reported in the study for Filipino culture are also prevalent in Chinese and Vietnamese cultures, but the study found no significant associations among these groups.

In summary, an evaluation of the limited available evidence on the effects of family psychosocial factors on smoking suggests that the effects of parental tobacco use, parental beliefs, and parent–child communication on adolescent tobacco use exist but are small and somewhat mixed across racial and ethnic groups. Further understanding of family-level protective factors that influence adolescent tobacco use can inform intervention efforts.

#### Peer Influences

According to the 2012 Surgeon General’s report, “smoking by one’s peers is a robust predictor of current smoking, regular smoking, and the transition to regular smoking and has a strong influence in adolescence” (USDHHS 2012, p. 559). The 2012 Surgeon General’s report further states that,

“Peer influences seem to be especially salient, perhaps because adolescence is a time during which school and peer group affiliations take on particular importance. Adolescents tend to over-estimate the prevalence of smoking among their peers, and perceptions that one’s peers smoke consistently predict use of tobacco. Another well-established finding is that adolescents are more likely to smoke if they have friends who smoke” (p. 563).

Given that the 2012 Surgeon General’s report provides strong evidence of the primary effect of peer influences on adolescent smoking initiation, this section highlights (1) studies that assess the relationship between peer smoking and smoking behaviors among adolescents from minoritized racial and ethnic groups and (2) evidence that explains how peer social norms shape smoking behaviors.

This section examines studies from the National Longitudinal Study of Adolescent to Adult Health (referred to as the Add Health cohort in this report), a nationally representative sample of 20,745 U.S. students in Grades 7–12 recruited from 132 schools in 1994–1995 (Wave I). The Add Health cohort has been followed across five waves (Add Health n.d.). Although the Add Health cohort predates electronic cigarettes (e-cigarettes) and some other currently available tobacco products commonly used by youth, the nationally representative sample enables within-person comparisons over time and allows for inference about peer influences regarding smoking.

Amin and Lhila (2016) applied a nonlinear decomposition method to data from Wave III (2001–2002 data collection) of the Add Health cohort, which resulted in a final sample of 14,679 adolescents. The study sought to determine the extent to which exposure to peer smoking or smoking in the home accounted for racial gaps in the prevalence of smoking among adolescents or the probability of smoking in young adulthood (18–24 years of age), while controlling for not smoking in adolescence and other sociodemographic variables. Results showed that White adolescents had the highest probability of having a mother who smokes, having cigarettes available in the home, and having a larger percentage of friends who smoke; they were also more likely to smoke themselves than were Black and Hispanic peers in adolescence and young adulthood, which the authors refer to as a “gap.” The authors found that peer social norms and exposure to smoking in the home accounted for 26–50% of this gap in smoking prevalence during adolescence and young adulthood between White and Black people and between White and Hispanic people in the cohort. The study authors noted a limitation of this study, namely that other unmeasured endogenous variables are potentially correlated with outcomes and may underestimate the effect of peer smoking. This study suggests that exposure to peer smoking or smoking in the home account for some of the racial and ethnic gaps observed in rates of smoking among youth. Future research could consider the typical later onset of smoking among Black people and the light daily smoking pattern among Hispanic American people who smoke.

Social popularity among teens has been hypothesized to influence adolescent smoking. In another analysis of data from the Add Health cohort from 1995 (Wave I), Robalino and Macy (2018) examined how smoking among popular adolescents in a particular grade influenced future prevalence of smoking among their peers. To measure the popularity of students in a grade, the authors analyzed school social network data for 7,500 students and calculated a smoking propensity score for students according to quintiles of popularity. The study found that greater popularity of students who smoked increased the probability of individual smoking for other students in the same grade level. Specifically, the results showed that if the top 20% of the most popular teens in a grade smoked, then the probability of non-smoking youth trying cigarettes the following year increased by 17.8% (P = .01). In contrast, to reduce the probability of future smoking, 80% of the least popular teens would need to not smoke. These peer-related effects persisted 7 years (Wave III) and 14 years (Wave IV) later. Although this analysis did not focus on disparities, the authors reported that correlates of unpopularity included being Black, Hispanic, overweight, and being an immigrant youth. These results suggest that smoking among a small proportion of popular teenagers can inform social norms in favor of smoking among other youth. It is possible that social influences on tobacco use patterns for youth from minoritized racial and ethnic groups and other groups (e.g., youth who identify as lesbian, gay, bisexual, transgender, queer, or intersex [LGBTQI+]) are mechanistically different from those of their popular and nonpopular peers, which warrants further research.

Many studies on how social factors affect adolescent smoking rely on self-reports of tobacco use among members of one’s own social network, which is subject to recall bias and social desirability effects. To help overcome this limitation, Hatzenbuehler and colleagues (2015) conducted a social network analysis using Add Health cohort data on 14,319 adolescents. Their analysis of adolescents’ reported friendship networks, which was matched with the friends’ reported tobacco use, resulted in an objective measure of the number of people who used tobacco in each friendship network. Consistent with past studies (Hoffman et al. 2006), Hatzenbuehler and colleagues (2015) found that adolescents’ smoking intensity correlated positively with the smoking intensity of other adolescents in their friendship network. A separate analysis found no significant moderation by LGBT status; the association between friends who smoked and smoking by the respondent was equally as strong among adolescents who were LGBT as it was among adolescents who were heterosexual.

In a longitudinal study that followed 1,950 students in 9th and 10th grades from Southern California schools for 2 years, Valente and colleagues (2013) conducted a social network analysis on perceived peer smoking and the influence of popular peers on adolescent smoking. Data were collected from seven urban schools with predominantly Hispanic students. Given that youth may overestimate their peers’ smoking behaviors, the authors tested the hypothesis that egocentric measures of friends’ smoking (i.e., perceptions of friends’ smoking behaviors) are more strongly associated with individuals’ smoking behavior than with sociometric measures (i.e., friends’ self-report of smoking behaviors). Models were adjusted for sociodemographic variables. As hypothesized, an egocentric measure of perceived friend smoking was positively and consistently associated with individual smoking. The sociometric measure of friends’ self-reported smoking was associated only with smoking in the ninth grade (based on a cross-sectional analysis). Finally, increased popularity was associated with adolescents’ becoming people who smoke (based on a longitudinal analysis). Adolescents tended to inaccurately estimate their friends’ smoking status. Findings suggest that peer influence and social context affect adolescent smoking behavior among Hispanic adolescents in urban school settings. Findings may not generalize to social dynamics at nonurban schools with low enrollment of Hispanic students or for adolescents not in school. Future research could identify mechanisms of peer influence and social context among popular teens and how they influence the use of a range of tobacco products among adolescents and additional groups by race, ethnicity, sexual orientation and gender identity, and other factors.

It is also important to understand social influences, including descriptive norms, on adolescents’ beliefs, by race and ethnicity, about e-cigarettes. Agaku and colleagues (2020) utilized the cross-sectional data from the National Youth Tobacco Survey (NYTS) from 2016 to 2017 to examine associations between exposure to secondhand e-cigarette aerosol and secondhand tobacco smoke in public places and (a) overestimation of peer e-cigarette use (a measure of descriptive norms), (b) harm perceptions of e-cigarettes, and (c) susceptibility to e-cigarette use among 24,353 U.S. middle and high school students who had never used tobacco products. Among all youth in this analysis, exposure to secondhand e-cigarette aerosol and secondhand tobacco smoke was associated with increased adjusted odds of overestimating peer e-cigarette use and decreased odds of perceiving e-cigarettes to be harmful, compared to those not exposed to secondhand e-cigarette aerosol or secondhand tobacco smoke. Compared to White youth, Hispanic youth had higher adjusted odds of overestimating peer vaping, curiosity, and susceptibility to vaping and lower adjusted odds of reporting harm perceptions. Black youth had lower harm perceptions and greater curiosity about vaping relative to White youth.

In an online survey of 1,549 U.S. teens (13–18 years of age) who had ever tried e-cigarettes or other electronic nicotine delivery systems (ENDS), Groom and colleagues (2021) found that the odds of reporting a friend as the source of their first ENDS product differed significantly by race and ethnicity, urbanicity of residence, and level of family income. The odds of trying their first ENDS product while “hanging out with friends” was significantly higher among teens who were non-Hispanic White, Hispanic, members of higher income families, and had received ENDS advertising and marketing through social media than it was among teens who were non-Hispanic Black, members of lower income families, and had received ENDS advertising and marketing through nonsocial media sources.

Hong and colleagues (2012) also explored, through a survey of African American and White 9th- and 12th-grade students in Louisiana, descriptive social norms and injunctive social norms on tobacco use. Descriptive social norms were defined by how many friends of a person smoked cigarettes, and injunctive social norms involved how the friends of a person would react if that person smoked cigarettes. Race moderated the relationship between descriptive norms and smoking behavior for students in 12th grade but not in 9th grade. At high levels of endorsement of descriptive norms, White students in 12th grade had a significantly higher prevalence of smoking than their African American counterparts. In contrast, injunctive norms did not influence smoking behavior in either group.

Studies examining peer influences on smoking tend to focus on adolescents. However, a study of urban, African American adults who smoked (Crossnohere et al. 2020) examined, with stratification by gender (n = 200 women, n = 335 men), the association between nicotine dependence and cessation norms and quitting behaviors. The term descriptive social norms was defined as having friends who quit smoking, and the term injunctive social norms was defined as having friends who disapproved of smoking. Findings showed that the inverse relationship between nicotine dependence and quitting behavior was attenuated for African American men with moderate-to-high dependence if they had friends who quit smoking; quit attempts by African American men were not influenced by friends’ disapproval of smoking, controlling for having friends who quit smoking. However, quit attempts by African American women were not influenced by type of social norm or level of nicotine dependence, suggesting different environmental or social factors influence quitting behaviors among Black men and women. Results emphasize the importance of stratification by gender when examining the role of social norms on smoking, particularly among African American people.

In summary, peers exert strong influences on smoking during adolescence. White adolescents may be particularly influenced by the social context in which smoking occurs. Additional cultural variables might also influence smoking trajectories for adolescents from minoritized racial and ethnic groups. Future studies could identify the factors and mechanisms driving the use of multiple tobacco products and the smoking cessation behaviors of youth and adults from groups that are disproportionately affected by tobacco-related health disparities.

#### Interaction of Family and Peer Influences

Research into factors that influence adolescent smoking has focused primarily on either family influences or peer influences. Family and peer influences are not truly independent, however, because family factors can affect peer interactions and vice versa. To begin to address this gap, Brook and colleagues (2010) followed a schoolbased sample of 475 African American and Puerto Rican adolescents living in Harlem, New York City, from adolescence to their mid-20s. The study tested a theoretical model positing that parent–child conflict during adolescence leads to (a) cigarette smoking during adolescence and (b) affiliation with peers who use drugs and exhibit antisocial behaviors in early adulthood. The positive association the authors found between parent–child conflict during adolescence and smoking status during early adulthood was mediated by children’s involvement in antisocial behavior and affiliation with peers who used drugs; however, this association did not differ between African American and Puerto Rican people or by sex. A statistically significant association was also found between affiliation with peers who used drugs in early adulthood and smoking status during that period, but again, did not differ between African American and Puerto Rican people or by sex. Findings from this longitudinal study show that characteristics of parental and peer relationships during adolescence can influence young adult cigarette smoking for African American and Puerto Rican people.

#### Summary and Future Research

The evidence reviewed in this section demonstrates that social influences from family members and peers are associated with adolescent smoking, and there may be important differences in these associations by race and ethnicity and by sex. Studies reviewed in this section demonstrate that parental smoking is associated with adolescent smoking, and this relationship is consistent across adolescents from various racial and ethnic groups. The findings from cross-sectional and longitudinal studies also suggest a relationship between parenting behaviors and characteristics (e.g., connectedness, monitoring, punishment, antitobacco communication, parent–adolescent decision making, negative family interactions) and adolescent smoking. However, there may be differences in some of these associations by race and ethnicity and by gender.

Data from the studies reviewed in this section demonstrate that peer smoking is associated with smoking among White, Black, and Hispanic American adolescents, and that greater exposure to peer and family smoking among White adolescents may help to account for gaps in smoking prevalence observed between White youth and youth from other racial and ethnic groups. Additional peer influences that may be associated with adolescent smoking include the prevalence of smoking among the most popular students at school, friends’ smoking intensity, and peer social norms. Some of these relationships also vary by race and ethnicity among adolescents.

A limitation of the literature to date is its emphasis on cigarette smoking behaviors. Although cigarette smoking has declined since 1991, data from the NYTS show that the prevalence of use of other forms of tobacco has increased among youth, and e-cigarettes have been the most commonly used tobacco product among middle and high school students since 2014 (Gentzke et al. 2019; National Academies of Sciences, Engineering, and Medicine 2020). Furthermore, the prevalence of cigarette and cigar use has been similar among youth in recent years (Gentzke et al. 2020; Park-Lee et al. 2022), but this is not consistent across population groups. For example, in 2020, the prevalence of cigar use was more than twice as high among Black youth (6.5%; 95% confidence interval [CI], 5.2–8.2) than White youth (2.8%; 95% CI, 2.1–3.7) (Gentzke et al. 2020). Most of the studies reviewed in this section that examined disparities in peer and parental influences on tobacco product use among adolescents included data that preceded the use of e-cigarettes by adolescents. Furthermore, much of the literature did not account for multiple tobacco product use. Thus, more research is needed to determine whether disparities exist in (a) the strength of family and peer influences on tobacco product use across the lifespan (from adolescence into older adulthood), as people transition from infrequent use to heavier use and develop nicotine dependence; and (b) the relationship between family and peer influences and e-cigarette use, as well as the use of multiple types of tobacco products among adolescents from various racial and ethnic groups. Finally, additional research is needed that examines the impact of family and peer influences on tobacco product use among American Indian and Alaska Native adolescents and among adolescents by other demographic characteristics, such as sexual orientation and gender identity, SES, and geographic region.

### Tobacco Product Use, Religion, and Culture

Religious influences are part of the larger social environment in which individuals, families, and peers may develop perceptions about tobacco use and beliefs about its social and physical effects (USDHHS 2012). Religions generally constrain the use of tobacco, despite large variations in their doctrines, and some forbid it altogether—such as Islam (Garrusi and Nakhaee 2012) and the Church of Latter-day Saints (Merrill and Thygerson 2001). Some populations of American Indian communities view tobacco as sacred, preserving its use for healing and ceremonial purposes. Chapter 1 of this report outlines the history of the commercialization of sacred and ceremonial tobacco.

Use of certain tobacco products has also been linked to cultural practices. In parts of South Asia and the Pacific Islands, crushed areca nut (also called betel nut, betel quid, or betel paan) is typically used as part of a mixture that often contains tobacco and other additives or flavorants (e.g., cardamom, sugar), which is chewed and has stimulant effects on the nervous system via absorption through the buccal mucosa (IARC Working Group on the Evaluation of Carcinogenic Risks to Humans 2004). Betel nut, which is also referred to as cultural smokeless tobacco (CST) when used for cultural practices among aggregate populations of Asian American people in the United States, can also be used as part of Hindu practices or social customs among people with ties to South Asia, the Middle East, or the Pacific Islands (Niaz et al. 2017; Mukherjea et al. 2018). In the 2004 cross-sectional California Asian Indian Tobacco Use Survey of 1,618 South Asian people surveyed in California, factors associated with CST use included being male, being 50 years of age and older, being an immigrant, speaking an Asian Indian language at home, having attained a higher level of education (i.e., high school/some college), having a higher income, identifying as non-Sikh, and disagreeing that spiritual beliefs are the foundation of life (Mukherjea et al. 2018). Health effects from frequent betel nut use include having discolored teeth and gums, activating the sympathetic nervous system, and developing oral cancers (IARC Working Group on the Evaluation of Carcinogenic Risks to Humans 2004). The causal relationship between the use of smokeless tobacco (with or without areca nut) and oral cancers has been consistently supported in the literature (NCI 2014; Niaz et al. 2017), and such use is associated with the high incidence of oral cancers in India (Mishra et al. 2012; Mukherjea et al. 2014).

Although the prevalence of the use of smokeless tobacco with or without areca nut is estimated to be the highest in India (25.9%) and Bangladesh (27.2%), rates are notable across the Middle East, North Africa, and the Pacific Islands (Niaz et al. 2017). Among a population-based sample of self-identified immigrants from India (analytic sample of 2,140 participants) to the United States (California), 65% had ever used a CST product, whereas only 25% had ever used commercial tobacco (cigarettes, cigars, pipes, chewing tobacco, snuff) (Patel et al. 2018). Practices and social customs involving the use of CST warrant further investigation; such information might be integrated into culturally sensitive tobacco prevention and treatment interventions for people from racial and ethnic groups who are known to use CST.

#### The Role of Religion in Differences in the Prevalence of Smoking Between Black or African American and White People

The 2012 Surgeon General’s report, Preventing Tobacco Use Among Youth and Young Adults (USDHHS 2012), described several studies in which the prevalence of smoking was lower among people who participated in religious activities compared with those who did not, or in which religious traditions served as protective factors against escalation of smoking. In a cross-sectional analysis of 4,776 Black and White 11th graders enrolled in a longitudinal study, findings showed that although Black adolescents had stronger religious beliefs against smoking than White adolescents, the protective effects of religion against smoking were stronger for White adolescents than Black adolescents (Alexander et al. 2016). The effect may be attributable to private religiosity (e.g., frequency of prayer), role modeling or monitoring by parents, less tobacco use among religious peers, or other factors (USDHHS 2012).

Although several studies have examined the role played by religion and cultural identity in the prevalence of smoking within a population, few studies have considered how the association may widen or diminish gaps in tobacco use between population groups. In one such study, Holt and colleagues (2015) examined a nationwide sample of 2,370 African American adults and found that religious behaviors, such as church attendance, were protective against current smoking, but religious beliefs and spiritual locus of control (i.e., beliefs in the role of a higher power on health, which can have an active or passive dimension) were not protective against current smoking. This pattern was similar in men and women. Findings suggest that aspects of church fellowship might discourage smoking more than religious beliefs for African American adults. In another study, Horton and Loukas (2013) found in a group of 984 community college students in Texas that positive religious coping (e.g., mobilizing resources in times of stress, such as by seeking spiritual support) decreased the likelihood of smoking cigarettes and cigars or cigarillos among White, but not African American, students. Negative religious coping (e.g., spiritual struggles or discontent with God) increased the likelihood of cigarette smoking among White students and cigar or cigarillo smoking among both White and African American students. One implication from this study is that training counselors whose practice is based on religious theology in evidence-based tobacco treatments and increasing their knowledge of cessation resources might discourage smoking among college students who engage in religious coping.

Future research could investigate how religious factors that discourage smoking can best be applied to community prevention and treatment intervention materials for people from racial and ethnic groups who use tobacco products and are oriented closely to a religion.

### Discrimination and Racism

Discrimination—the prejudicial treatment of individuals based on their actual or perceived membership in a minoritized, lower SES, or stigmatized group—has been associated with adverse health outcomes and health behaviors, including smoking (Pascoe and Smart Richman 2009; Williams et al. 2019). In the CLD model (Figure 4.1), experiences with discrimination are considered a fundamental factor that leads to an increased stress response and symptoms of anxiety, which, in turn, positively correlate with smoking (Mills et al. 2023). The transactional theory of stress, appraisal, and coping undergirds most of the research examining the relationship between discrimination and smoking (Lazarus and Launier 1978; Lazarus and Folkman 1984). When applying this model to tobacco-related health disparities, social stressors, such as discrimination experiences, may create a causal pathway to smoking for people who experience discrimination. The CLD model encompasses stress and coping theory by visually depicting the positive feedback loop of discrimination experiences as an acute or chronic stressor and coping through smoking or use of other tobacco products. The model also shows the association between experiences with discrimination and structural racism that can occur through a process of marginalization for people from racial and ethnic groups (Williams et al. 2019; Mills et al. 2023).

The 1998 Surgeon General’s report on Tobacco Use Among U.S. Racial/Ethnic Minority Groups identified racism as contributing to “different rates of illness across racial/ethnic groups” (USDHHS 1998, p. 11). Through a review of empirical studies, the report also noted that “experiences with discrimination and racism” (USDHHS 1998, p. 11) were explanatory factors for the different rates of tobacco-related disease that occur by race and ethnicity. However, the authors of the report determined that scientific methods had yet to delineate the role of acculturation, SES, and societal problems such as racism, prejudice, and discrimination in shaping tobacco use patterns among Black or African American, Asian American, Pacific Islander, Hispanic or Latino, or American Indian and Alaska Native people. Since the publication of the 1998 Surgeon General’s report, research studies have sought to elucidate the role of discrimination and acculturation on racial and ethnic disparities in tobacco use and disease. This research is reviewed in the next two sections.

A 2019 review of the literature examined how racial discrimination functions at three levels (individual, institutional, and cultural) to affect physical and mental health outcomes among racial and ethnic groups in the United States. The review concluded that, interactively, these three levels of discrimination “are a fundamental cause of adverse health outcomes for racial/ethnic minorities and racial/ethnic inequities in health” (Williams et al. 2019, p. 105). Numerous studies of diverse groups have demonstrated that perceived discrimination is associated with an increased risk of tobacco use, even after controlling for sociodemographic covariates. For example, Brondolo and colleagues (2015) reviewed 15 studies published between 1996 and 2010 for the association between discrimination and tobacco use; 12 of the 15 studies reported a positive association (i.e., experiencing discrimination was associated with greater tobacco use), and the other 3 studies did not report an association between discrimination and tobacco use.

It is important to understand whether the association between discrimination and tobacco use is stronger among some groups than among others. If the effects of discrimination on tobacco use are stronger among some groups, then the experience of discrimination could create or widen tobacco-related health disparities.

As such, this section summarizes findings from research published between 2008 and 2019 on the effects of discrimination on tobacco use and tobacco-related health disparities, starting with a discussion about discrimination measures commonly used in tobacco prevention and treatment research. The section only includes studies that examined differences in the association between discrimination and tobacco use across groups, either by testing discrimination–group interaction terms or initially stratifying the sample by group (e.g., race or ethnicity, sex) and then examining the association between discrimination and tobacco use separately within groups. Most relevant studies examined associations across racial or ethnic groups, but several examined associations across sex or sexual orientation and gender identity. References to discrimination in this section generally refer to discrimination on the basis of race and ethnicity, unless otherwise stated.

#### Measurement of Discrimination

Many survey studies of discrimination assess major lifetime experiences of unfair treatment and everyday experiences of chronic, routine, and relatively minor unfair treatment (Williams et al. 1997). The frequency of such experiences is assessed based on a variety of characteristics (e.g., race, ethnicity, gender, age, religion, physical attributes, sexual orientation, or other characteristics) and across varied life domains (e.g., receiving poorer service than other people at restaurants or stores; being unfairly fired or denied promotion; not being hired for a job; being unfairly stopped, searched, questioned, physically threatened, or abused by the police; being treated with less courtesy than other people; or people acting as if someone is not smart). Underlying this and other discrimination measures is a self-appraisal of how stressful the experience was and the pervasiveness of experiences across the lifespan (Williams et al. 1997). Studies measuring the discrimination construct tend to use terms interchangeably, such as self-reported discrimination, perceived discrimination, and discrimination experiences.

Additionally, self-reported types of discrimination may differ by race and ethnicity. In an online crosssectional panel survey of 2,376 adults who smoked, Kendzor and colleagues (2014) measured perceived everyday discrimination by the Everyday Discrimination Scale (Short Version; Sternthal et al. 2011). Discrimination on the basis of race, ancestry, national origin, physical appearance, and age were reported by African American and Hispanic people as the most common perceived reasons for experiences with discrimination; however, physical appearance, age, gender, and weight were reported by White people as the most common perceived reasons for experiencing discrimination.

#### Discrimination and Smoking

##### Differences by Race and Ethnicity

Several studies have found racial and ethnic differences in the association between experiences of discrimination and tobacco use, but the findings have not been consistent. In most of the reviewed studies that examined differences by race and ethnicity, the authors found a statistically significant association between discrimination and tobacco use behaviors among African American respondents but not among Hispanic respondents, while associations among White respondents and respondents from other racial and ethnic groups were mixed (Okechukwu et al. 2010; Nguyen et al. 2012; Horton and Loukas 2013; Brondolo et al. 2015; Chavez et al. 2015). For example, analyzing data from the 2004–2010 Behavioral Risk Factor Surveillance System (BRFSS) (pooled n = 70,080), Chavez and colleagues (2015) found a statistically significant association between experiencing workplace discrimination in the past year and current smoking (every day or some days) among White people (adjusted odds ratio [aOR] = 1.34; 95% CI, 1.19–1.53) and African American people (aOR = 1.32; 95% CI, 1.08–1.62) but not among Hispanic people (aOR = 0.92; 95% CI, 0.57–1.49) or people classified as “other” race or ethnicity (aOR = 1.57; 95% CI, 0.95–2.60). Purnell and colleagues (2012) also analyzed pooled data from the 2004–2008 BRFSS administrations (n = 85,130) to examine the association between discrimination in the workplace and healthcare domains and current smoking. Although this study found that current smoking was higher among people who reported being treated worse because of their race or ethnicity in healthcare settings (aOR = 1.18; 95% CI, 1.09–1.26) or in the workplace (aOR = 1.13; 95% CI, 1.03–1.23), the interaction between discrimination and race or ethnicity was not statistically significant. Stone and Elbers-Carlisle (2020) also found that, among 3,098 U.S. adults who participated in the Reactions to Race Module of the 2014 BRFSS, experiencing negative emotions based on treatment due to race was associated with current cigarette smoking in non-Hispanic Black adults. Given these inconsistent findings, future analysis of population survey data examining the discrimination–smoking association in healthcare and workplace settings could stratify results by race or ethnicity, consider intersectionality (e.g., of race and ethnicity with SES), and identify other explanatory variables.

In another study of 518 African American and Hispanic ambulatory care patients in New York City, Brondolo and colleagues (2015) found that the association between perceived recent discrimination and daily smoking was statistically significant among African American patients (OR = 2.08; 95% CI, 1.18–3.66) but not among Hispanic patients. Furthermore, Horton and Loukas (2013) analyzed data from a cross-sectional study of 984 technical and vocational school students in Texas and found statistically significant associations between perceived discrimination and (a) frequency of cigarette smoking among African American students and (b) frequency of cigar and cigarillo use among White and African American students, but neither association was significant for Mexican American students.

In a cross-sectional survey of 1,282 working-class union members in Boston, Okechukwu and colleagues (2010) found an association between workplace racial discrimination and smoking in the past week among African American workers (OR = 1.12; 95% CI, 1.01–1.25) but not among White workers, Hispanic workers, or workers from other racial and ethnic groups. In addition, this study found that workplace discrimination was associated with past-week cigarette use among immigrants (OR = 1.13; 95% CI, 1.03–1.24) but not among U.S.-born workers. However, the discrimination–group interaction terms were not statistically significant, suggesting a potential role of acculturation (as measured by nativity status) in the discrimination–smoking relationship. The acculturation–smoking relationship is discussed later in this chapter.

In a cross-sectional study of smoking among pregnant African American and Hispanic women in Boston (N = 677), Nguyen and colleagues (2012) found that African American women were more likely to smoke during pregnancy (OR = 3.36; 95% CI, 1.23–9.19) if they experienced discrimination in three or more of eight settings (in school, getting hired, at work, in housing, in medical settings, getting services, in public settings, or from the police/courts) than if they experienced discrimination in two or fewer settings. In models examining the relationship between discrimination and smoking by race and ethnicity, this association was only statistically significant for Black women (Nguyen et al. 2012). The authors reported this as the first study that found a link between experiences with discrimination and increased risk of smoking among pregnant women from racial and ethnic groups. Future research could use models stratified by race and ethnicity when examining other explanatory variables that interact with experiences with discrimination and tobacco use.

Most studies of racial and ethnic disparities have combined immigrants and U.S.-born respondents, which could introduce confounding because most Black or African American and White people in the United States are U.S.-born, and a large segment of U.S. Hispanic, Asian, and Pacific Islander populations are more recent immigrants (López and Radford 2017). In a cross-sectional study that focused on immigrants from Africa, Southeast Asia, and Latin America who were currently living in Minnesota (N = 1,387), Tran and colleagues (2010) found that the association between discrimination and current smoking was statistically significant among Southeast Asian immigrants (aOR = 1.60; 95% CI, 1.02–2.51) but not among Black people born in Africa or among Hispanic people. However, among Hispanic people, the association between discrimination and current smoking was significant for those who had lived in the United States for more than 7 years but not for recent Hispanic immigrants, suggesting that risk for tobacco use increases as Hispanic immigrants acculturate over time. Future longitudinal studies are needed to monitor how experiences with discrimination and smoking change over time as immigrants acculturate to life in the United States.

#### Discrimination, Nicotine Dependence, and Cessation

Few studies have focused on nicotine dependence or quitting and experiences with discrimination. Kendzor and colleagues (2014) measured the association between perceived everyday discrimination based on the Everyday Discrimination Scale (Short Version; Sternthal et al. 2011) and nicotine dependence and heavy smoking. Everyday discrimination was positively associated with dependence for Hispanic, African American, and White people, but the association was stronger among Hispanic people than it was among those in the other two groups. Everyday discrimination was positively associated with heavy smoking for Hispanic people but not for African American or White people. Findings suggest that everyday experiences with discrimination on the basis of race and ethnicity may lead to greater nicotine dependence and possibly a harder time quitting, particularly for Hispanic people who smoke cigarettes (Kendzor et al. 2014). Reinforcing these findings, Bello and colleagues (2021) found that, among 607 non-Hispanic African American adults in California who smoked cigarettes daily, increased perceived exposure to discrimination was associated with increased urges to smoke to alleviate negative moods. Furthermore, among 360 unemployed adults who lived in California and currently smoked, Fielding-Singh and colleagues (2020) found significant associations between experiencing stigma related to both unemployment and smoking and readiness to quit smoking.

In a longitudinal study of 190 Spanish-speaking people who smoked, identified as Mexican American, and were motivated to quit within a month, experiencing a greater number of major discrimination events was associated with a reduced likelihood of 7-day pointprevalence abstinence at 26 weeks post-quit date (Kendzor et al. 2014). Findings suggest that Mexican American people who experience discrimination may struggle with smoking cessation.

Webb Hooper and colleagues (2020) identified racial and ethnic differences in the relationship between perceived discrimination and smoking abstinence in a treatment-seeking sample of 347 non-Hispanic White, non-Hispanic African American/Black, and Hispanic (of any race) people who smoked and participated in a randomized controlled trial testing the effects of a group cessation intervention plus pharmacotherapy. In adjusted models, irrespective of race or ethnicity, past-year perceived discrimination, measured by the General Ethnic Discrimination scale (Landrine et al. 2006), was inversely associated with biochemically verified 7-day pointprevalence abstinence for African American/Black people and non-Hispanic White people, but not for Hispanic people, immediately post-intervention. At the 6-month follow-up, past-year discrimination predicted worse cessation outcomes for Black people only. Findings suggest that some experiences of racial and nonracial discrimination may disrupt the cessation process for people across all racial and ethnic groups who want to quit (Webb Hooper et al. 2020). Future research could examine the role of acute and chronic discrimination over time in the quitting process and measure sociocultural variables that could affect both perceived discrimination and smoking cessation outcomes.

##### Differences by Gender

Most studies on discrimination and smoking have focused on differences by race or ethnicity, but a few studies have focused on differences by gender. Brondolo and colleagues (2015), in their study of 518 African American or Hispanic ambulatory care patients in New York City, found that the association between discrimination and smoking was statistically significant among men (OR = 2.63; 95% CI, 1.33–5.16) but not among women. Earlier, a 5-year followup survey of African American and Hispanic adolescents enrolled in the Moving to Opportunity for Fair Housing study by Wiehe and colleagues (2010) found differences by gender in the association between racial or ethnic discrimination and past-month smoking. Adolescent boys who reported discrimination in any setting (e.g., at school or work, in the neighborhood, in shops, or by law enforcement) had significantly higher odds of past-month smoking (OR = 2.0; p <0.05). However, adolescent girls who reported discrimination had significantly lower odds of past-month smoking (OR = 0.5; p <0.05), which, in post hoc analyses, was driven by pregnancy status; girls who had been pregnant were significantly less likely to report smoking in the context of discrimination experiences (OR = 0.30; 95% CI, 0.10–0.92), whereas girls who had never been pregnant had no statistically significant discrimination–smoking relationship. This research highlights the need for future studies to identify other potential explanatory variables that relate to gendered experiences with discrimination and smoking.

##### Differences by Sexual Orientation and Gender Identity

This section examines the relationship between discrimination and smoking among people who identify as LGBTQI+ and focuses on differences in tobacco use by sexual orientation and gender identity. In an analysis of data from the 2012–2013 National Epidemiologic Survey on Alcohol and Related Conditions, a nationally representative, cross-sectional sample of noninstitutionalized U.S. adults, approximately half of people who identified as lesbian or gay and one-fourth of people who identified as bisexual reported past-year sexual orientation discrimination (McCabe et al. 2019). People who identified as lesbian, gay, or bisexual and who experienced high levels of past-year discrimination based on sexual orientation had a statistically significantly greater probability of past-year cigarette smoking, any tobacco/nicotine use, and having a tobacco use disorder based on criteria from the fifth edition of the Diagnostic and Statistical Manual of Mental Disorders (American Psychiatric Association 2013) compared with their counterparts who experienced lower levels of discrimination or no discrimination based on sexual orientation.

Most of the social science research on this topic has focused on self-reported perceptions of discrimination; however, the field is beginning to examine structural social determinants of stigma as potential contributors to the discrimination–smoking relationship. In a longitudinal study of 16,882 U.S. youth from the Growing Up Today Study, Hatzenbuehler and colleagues (2014) found that youth who identified as lesbian, gay, or bisexual and lived in states with substantial structural stigma—as measured by a multidimensional structural stigma index score that accounted for school-level social support resources for lesbian, gay, and bisexual youth; prevalence of samesex partner households; public opinion toward people who identify as lesbian, gay, and bisexual; and statewide protective policies for lesbian, gay, and bisexual youth—were more likely to smoke in the past year than their counterparts who resided in states with a lower structural stigma index score. Residing in a state with a higher structural stigma score was a unique risk factor for smoking among lesbian, gay, and bisexual youth; their heterosexual counterparts residing in states with high levels of structural stigma were no more likely to smoke than those living in states with low levels of structural stigma. However, this study did not assess transgender identity. Additionally, the study population included the children of women who participated in the national Nurses’ Health Study II cohort, which consisted of a sample of mothers, most of whom were White, in the nursing workforce and their children. Therefore, findings do not fully represent the diversity of adolescents from racial and ethnic groups and may not be generalizable to those whose parents do not work in the healthcare industry.

In an analysis of a national, probability-based sample of 11,949 LGBT adults and 352,343 non-LGBT adults in the United States (Hatzenbuehler et al. 2017), LGBT respondents were more likely to smoke and to report fair or poor self-rated health compared with non-LGBT respondents. Further, when structural stigma—measured by county-level attitudes toward same-sex marriage (i.e., in favor of vs. opposed to)—was included in multivariate models, results showed that higher levels of local approval of same-sex marriage were associated with a lower probability of LGBT and non-LGBT adults reporting smoking and fair or poor self-rated health. However, this study reported only an 11% response rate overall, and race and ethnicity were controlled in models, thus restricting identification of possible racial and ethnic differences in the association between attitudes toward same-sex marriage and smoking among LGBT and non-LGBT adults.

Elsewhere, Blosnich and Horn (2011) examined the association between discrimination and smoking status among 11,046 lesbian, gay, and bisexual college students and their heterosexual counterparts, 18–24 years of age. Although the prevalence of smoking and the prevalence of discrimination were both higher among the lesbian, gay, and bisexual group than among heterosexuals, the association between discrimination and smoking was not statistically significant in either group. This study measured discrimination with a single-item dichotomous measure, which might have been less sensitive than the multi-item measures used in other studies.

Finally, Lipperman-Kreda and colleagues (2019) examined the role of perceived stigma among 227 adults in California who identified with a sexual and gender minority population (the term used in the study). The study found interacting effects between perceived stigma related to smoking and adults of African American race who were experiencing housing insecurity. More specifically, among adults who currently or formerly smoked and were experiencing housing insecurity, those who identified as African American and with a sexual and gender minority population were more likely to experience perceived stigma related to smoking than were non-African American adults who identified with a sexual and gender minority population.

Overall, the evidence from these studies suggests that measures of social determinants of health can add a multidimensional perspective on the effect of discrimination on smoking among people from sexual orientation and gender identity groups. The evidence also suggests that the minority stress model (Hamilton and Mahalik 2009), which asserts that racial discrimination contributes to stress-related cigarette smoking, could be extended to understand the link between discrimination and smoking among sexual orientation and gender identity groups. Future research could consider the interactive effects of individual-level perceptions of discrimination and social determinants of health to inform culturally tailored prevention and cessation interventions for this population.

#### Discrimination and the Use of Other Tobacco Products

Few studies have examined the discrimination–tobacco use association for tobacco products other than cigarettes. One such cross-sectional study used an online sample of 1,068 U.S. adults and examined associations between perceived discrimination and use of six tobacco products (cigarettes, e-cigarettes, cigars, pipe tobacco, hookah, and smokeless tobacco) (Unger 2018). Perceived discrimination was a risk factor for current use of all the products except smokeless tobacco, with aORs ranging from 1.42 to 1.77. However, none of the interaction effects between discrimination and demographic characteristics (race and ethnicity, sex, age group, level of educational attainment, and level of income) were statistically significant, indicating that the associations between discrimination and current use of each product were similar across demographic groups. Rogers and colleagues (2018) analyzed the same dataset of 1,068 U.S. adults and assessed racial and ethnic differences in the association between measures of two stress domains—discrimination and financial strain (e.g., difficulty paying bills, difficulty making ends meet, putting off buying needed items, and other indicators)—and the use of combustible tobacco or e-cigarettes. They found that the association between discrimination and use of combustible tobacco products (i.e., cigarettes, cigars, pipe tobacco, or hookah) was statistically significant among African American (aOR = 1.97; 95% CI, 1.17–3.32), Hispanic (aOR = 2.81; 95% CI, 1.74–4.54), and Asian American and Pacific Islander people (aOR = 3.13; 95% CI, 1.57–6.22) but not among White people. Conversely, the association between discrimination and use of e-cigarettes was statistically significant among White (aOR = 1.23; 95% CI, 1.02–1.47), Hispanic (aOR = 2.58; 95% CI, 1.61–4.13), and Asian American and Pacific Islander people (aOR = 3.66; 95% CI, 1.74–7.70) but not among African American people. The association between financial strain and combustible tobacco use was significant for White (aOR = 1.27; 95% CI, 1.15–1.39) and Black people (aOR = 1.59; 95% CI, 1.14–2.22), but not Hispanic or Asian American and Pacific Islander people. Financial strain was associated with higher odds of e-cigarette use for White (aOR = 1.13; 95% CI, 1.02–1.25) and Black people (aOR = 1.44; 95% CI, 1.06–1.97) and with lower odds of e-cigarette use among Asian American and Pacific Islander people (aOR = 0.50; 95% CI, 0.26–0.97); financial strain was not associated with e-cigarette use among Hispanic people. Both analyses (Rogers et al. 2018; Unger et al. 2018) are limited in that most survey participants were White (79%) and had at least some college education (58%), and subgroup analysis included small samples of other racial and ethnic groups and people of lower SES. Thus, sample size may have been too small and may have lacked the statistical power to detect effects for some demographic groups. This precludes more definitive statements of whether racial or ethnic differences exist in the relationship between discrimination and other tobacco product use in the United States. Longitudinal studies that oversample diverse racial and ethnic, socioeconomic, and sexual orientation and gender identity groups are needed to examine the relationship between discrimination and the use of noncigarette tobacco products.

Earlier, a study by Nollen and colleagues (2016) used an intersectionality approach to identify the high-risk population groups (defined by membership in two or more disparity groups) that were most likely to use other tobacco products (e.g., cigars, cigarillos, little cigars, smokeless tobacco, pipes, hand-rolled cigarettes, and hookah) in addition to cigarettes. In an online survey panel of 1,584 people who smoked cigarettes, the groups with the highest likelihood of using one or more other tobacco products in addition to cigarettes were (a) women younger than 45 years of age who were Hispanic or African American and had experienced high levels of discrimination (62% used other tobacco products in addition to cigarettes) and (b) men with alcohol use disorders (74% used other tobacco products in addition to cigarettes). People who smoked cigarettes with all other combinations of these factors were less likely to use other tobacco products than the people who smoked cigarettes in the aforementioned two high-risk groups. Although this study indicates that noncigarette tobacco product use is associated with experiences with discrimination for women from racial and ethnic groups, the study did not assess e-cigarette use, which is an important limitation.

#### Summary and Recommendations

Studies have found a strong and consistent positive association between discrimination and tobacco product use among Black or African American people, but inconsistent effects among Hispanic or Latino and White people. Further, the relationship between discrimination and smoking may vary by immigration status, as one study found a strong association among immigrants from Southeast Asia. The studies reviewed in this section also demonstrated that the association between discrimination and smoking may differ across genders and races and ethnicities. Structural stigma related to same-sex marriage and experiences of discrimination on the basis of sexual orientation are also associated with an increased likelihood of smoking among LGBTQI+ people. Finally, evidence suggests that experiences of discrimination may have adverse consequences for smoking cessation among people who smoke. Although the findings were not consistent, this relationship may vary by race and ethnicity.

One limitation of the literature reviewed in this section is that because most studies used cross-sectional data to examine cigarette smoking among adults, the evidence is not sufficient to determine the causal role of discrimination in disparities in tobacco product initiation, use, and cessation across a person’s lifespan. For some groups, experiences of discrimination can fluctuate during a person’s lifespan, while other groups may have chronic experiences of discrimination that persist across the lifespan. Because tobacco product initiation typically occurs during adolescence and young adulthood, longitudinal studies are needed to identify populations that are most strongly impacted by discrimination at each stage of the tobacco use continuum during adolescence and adulthood. It is also important to determine whether these patterns are consistent across other types of tobacco products in addition to cigarettes. Data from one cross-sectional study suggest that there may be an association between discrimination and use of other tobacco products, such as e-cigarettes, cigars, pipe tobacco, and hookah. However, additional observational studies are needed to examine (a) the association between discrimination and all current and emerging tobacco products and (b) any potential disparities that persist in these relationships.

Another limitation of the literature reviewed in this section is that many studies have examined individuallevel experiences of racial discrimination. Research rarely examines the effects of institutional-level discrimination on tobacco product-related outcomes, which is an area for future study. Examining the mechanisms through which discrimination within and across systems, institutions, and policies can affect tobacco product initiation, use, and cessation will foster a more complete understanding of the causes of tobacco-related disparities. Future research could utilize multilevel studies to investigate the impact of discrimination experienced across the life course among people with multiple and intersectional identities. Furthermore, although a few studies have looked at the impact of discrimination in the workplace or when receiving healthcare, additional research is needed to elucidate the associations between discrimination experienced in various settings across the life course and tobacco-related health outcomes. Future research could also use external measures of discrimination and compare them with psychometrically rigorous, self-reported survey responses to enhance the reliability and validity of the discrimination construct as it relates to elucidating the field’s understanding of pathways from experienced discrimination to tobacco use and tobacco-related health disparities.

### Acculturation

The 1998 Surgeon General’s report concluded, “the data in general suggest that acculturation influences smoking patterns in that individuals tend to adopt the smoking behavior of the current broader community; however, the exact effects of acculturation on smoking behavior are difficult to quantify because of limitations on most available measures of this cultural learning process” (USDHHS 1998, p. 94). This review updates the literature examining the relationship between acculturation and smoking for immigrants and nonimmigrants who identify as Hispanic American, Asian American, or African American based on advances in the field in subsequent decades. This section begins by introducing the acculturation concept. Next, it discusses the measurement of the acculturation concept. This section also reviews diverse approaches to disentangling the relationship between acculturation and smoking-related behaviors, with consideration of interactions with gender and other sociocultural factors relevant to smoking for racial and ethnic populations. Findings are reported for disparity groups based on the available U.S. data, with a focus on peer-reviewed systematic reviews. Studies examining the relationship between acculturation and smoking cessation had small sample sizes and are only included because cessation trials with larger samples have yet to be published. The section includes an overall summary and recommendations for future research examining relationships between acculturation, smoking, and tobacco-related health disparities.

#### The Acculturation Concept

Acculturation represents the changes in individuals’ practices, values, and identifications that occur as a result of contact with culturally dissimilar people, groups, or social influences (Schwartz et al. 2010). It is widely regarded as an important area of study for smoking prevention and treatment research focused on racial and ethnic groups in the United States (Li and Wen 2015; Webb Hooper et al. 2018). The majority of acculturation- and tobacco-related studies focus on changes in the prevalence of cigarette smoking as it relates to acculturation among immigrants who are permanently living in the United States. Additionally, substantial literature exists on acculturation and cigarette smoking for African American people.

A four-level descriptive model has been widely used in the literature to represent the acculturation process for racial and ethnic groups (Berry 1997, 2022). According to this model, integration represents a person’s orientation to their ancestral culture or country of birth and the mainstream or dominant culture that prevails where they live (Berry 1997). The process of retaining practices, values, and social norms associated with the country of birth or ancestral culture is referred to as retaining culturally traditional identity; whereas, acculturation and assimilation are used interchangeably to describe movement toward the practices, values, and social norms of the dominant culture (Berry et al. 2006). To fully capture the complexity of the multiple bidirectional relationships that can occur during the acculturation process for racial and ethnic groups, descriptive terms such as integration, separation, marginalization, multiculturalism, biculturalism, melting pot, segregation, and exclusion are also used in the literature (Berry et al. 2006).

#### Measurement of Acculturation

Acculturation studies use varied self-report measurement approaches that range from a bidimensional, single-item proxy measure to multi-item, multidimensional self-report surveys. Multidimensional surveys typically consider the intersection of practices, values, social norms, and self-identity associated with a heritage culture and receiving culture (Schwartz et al. 2010).

Research on acculturation typically uses the following self-report proxy measures: preferred language and language ability, nativity (U.S.-born vs. foreign-born), time living in the United States, and generational status (e.g., immigrant or child of an immigrant). Longer acculturation measures assess multiple domains (e.g., practices, values, self-identities) and dimensions (e.g., level of acculturation to mainstream American culture and orientation to the heritage culture) of acculturation (Schwartz et al. 2010). For more than 30 years, extensive research has been conducted to examine relationships between acculturation proxies and smoking, as well as to develop psychometrically rigorous, multidimensional acculturation self-report surveys for racial and ethnic groups. However, multidimensional acculturation assessments can place a significant burden on participants because of their length, particularly as such scales are usually embedded within a larger survey instrument used in clinical and community-based research. Multidimensional acculturation surveys also are limited by reflecting the practices, values, norms, and identities of the time when researched and are less flexible to changes in cultural phenomena over time for racial and ethnic groups. The assessment and comprehension of acculturation reflects the complexity of human behavior, as some individuals within a racial or ethnic group may respond differently to cultural practices, values, and identities that are typically shared within a group (Berry 2003).

#### Findings from NCI Tobacco Control Monograph 22 and Subsequent Systematic Reviews

NCI Tobacco Control Monograph 22 reviewed and summarized 59 studies that were published between 2000 and 2011 and examined smoking behavior among immigrants; most studies documented an association between acculturation and smoking behavior (NCI 2017b). Most studies examined this relationship among Asian American or Hispanic American populations using a cross-sectional design. The report noted that “in general, foreign-born men are more likely to smoke than their U.S.-born counterparts; conversely, foreign-born women are less likely to smoke than U.S.-born women” (NCI 2017, p. 261). In the reviewed studies that had adolescent samples (n = 9), the acculturation–smoking association was usually indirect, with associations diminishing after controlling for such other variables as parental monitoring or access to cigarettes. In contrast, the smoking–acculturation association was typically stronger and more persistent in studies of adults. Associations also differed by gender and by ethnicity. For example, in a 2005 systematic review (Bethel and Schenker 2005), acculturation and smoking status were positively correlated among Hispanic American women (nine studies) but negatively correlated among Hispanic American men (one study). A significant inverse association was found between acculturation and tobacco dependence among Arab American men and women, among whom the heritage countries often have high smoking prevalence (Al-Omari and Scheibmeir 2009).

At least two systematic reviews examining the relationship between acculturation and cigarette smoking among racial and ethnic populations have been published since NCI Tobacco Control Monograph 22. A 2015 systematic review of the acculturation and smoking relationship in North American people of Chinese ancestry included 14 quantitative studies (11 adult and 3 adolescent studies; 11 U.S.-based studies and 3 Canadian studies) published between 2005 and 2013 and included 14,875 Chinese immigrants across all studies (Gotay et al. 2015). Language used in the home and duration of stay in North America were the most frequently used acculturation measures in this review (Gotay et al. 2015). The main effects from 10 of the 11 adult studies identified significant relationships (all in the same direction), suggesting that men who were more acculturated smoked less than their respective countrymen and women who were more acculturated smoked more than their respective countrywomen. The main findings from the three studies of North American youth of Chinese ancestry varied. For example, one study found that acculturation measured using the Short Acculturation Scale for Hispanics (i.e., an assessment of language use, media consumption, and ethnic social relations) (Marin et al. 1987) was not related to smoking for Chinese youth in Los Angeles County (Weiss and Garbanati 2006), and another found that acculturation measures did not explain the lower rates of smoking among Chinese youth compared to other groups of Toronto youth (Asbridge et al. 2005). Another study found that country of origin was related to smoking, as U.S.-born youth of Chinese ancestry were more likely to report smoking than were foreign-born youth of Chinese ancestry (Kaplan et al. 2008). None of the youth-focused studies in this review examined data separately for boys and girls, nor did they report on length of stay in North America (Gotay et al. 2015). Although this review identifies acculturation as measured by language use and time in a new country as important correlates of smoking for Chinese immigrants in the United States and Canada, it is limited by the reliance on self-reported, cross-sectional data collection methods, which can be influenced by social desirability effects (e.g., women of Chinese ancestry might experience more social pressure to report their status as a person who does not smoke compared with men of Chinese ancestry) and recall bias (Bethel and Schenker 2005).

A systematic review of 27 quantitative studies published between 1998 and 2013 focused on the acculturation–smoking relationship among adult immigrants (foreign-born) from non-Western countries (Western countries defined in this study as United States, Canada, Ireland, Germany, the Netherlands, Norway, the United Kingdom, and Australia). Sample sizes in these studies ranged from 96 to 16,738 people. Lower prevalence of smoking for men and higher prevalence of smoking for women among acculturated immigrants suggested movement toward social norms of the host country (i.e., United States) (Reiss et al. 2015). The direction of effects was the same in U.S.- and non-U.S. based studies. The review also considered the phase of the smoking epidemic in the immigrants’ country of origin at the time of migration (Lopez et al. 1994). The smoking epidemic concept is represented by a four-stage descriptive model developed by Lopez and colleagues (1994) that contextualizes shifts in the prevalence of smoking at the population level over time for men and women in the country of origin according to a measure of country-level economic development. The model was updated in 2012 to allow for different stages of the smoking epidemic to be described separately for male and female people (Thun et al. 2012). For example, China’s growing cigarette consumption after 1975 was at least partially influenced by cultural and social norms that encouraged smoking among men (Corrao et al. 2000). Consideration of where a country is in the smoking epidemic while examining other social and health-related correlates has been widely studied (Lopez et al. 1994; Chen et al. 1997; Pampel 2005; Ward et al. 2006; Singh et al. 2009; Narain and Sinha 2011; Reiss et al. 2015).

#### Role of Gender in the Acculturation and Smoking Relationship

NCI Tobacco Control Monograph 22 (NCI 2017b) found that the relationship between acculturation and smoking for immigrants in the United States is associated with gendered social norms for smoking from the country of origin, a finding upheld in more recent literature reviews (Gotay et al. 2015; Reiss et al. 2015). Given that differences in the prevalence of smoking by gender are established before people immigrate to the United States (Zhang and Wang 2008), it is important to stratify studies of the acculturation–smoking relationship by gender or to ensure that study designs give consideration to baseline gender differences in the prevalence of smoking rather than controlling for gender or identifying gender differences only during the analysis phase.

Since the release of NCI Tobacco Control Monograph 22, a meta-analysis was published that examined the acculturation–smoking relationship in 39,777 Hispanic American adult women and adolescent girls, which included 26 quantitative studies published between 1990 and 2010 that used various measures of acculturation (Kondo et al. 2016). Findings showed a consistent positive association between immigration status and cigarette smoking in Hispanic women, which was moderated by age (i.e., a larger effect in adults versus adolescents); country of birth; and if analysis included dichotomous or multivariable measures of acculturation. The average unstandardized effect size of acculturation on smoking was modest (OR = 1.81; 95% CI, 1.57–2.07) across all studies. Studies that included Mexican American women had the largest effect between an acculturation measure and current smoking compared to studies of women from other Latin American countries, underlying the importance of disaggregated measures of Hispanic American ethnic groups in acculturation studies (Rodriquez et al. 2019).

#### Acculturation and Smoking Among Black or African American People

For Black or African American people, a heterogeneous racial group consisting of people of African descent living in the United States, the most widely used selfreport measures of acculturation are unidimensional and multidimensional scales that assess orientation to the traditions, values, social norms, and self-identity linked to African American culture (Landrine and Klonoff 1994; Snowden and Hines 1999; Klonoff and Landrine 2000; Obasi and Leong 2010). Survey items tend to be oriented to the descendants of enslaved African people with centuries of generations living in the United States rather than those of African immigrants. Acculturation surveys for African American people have undergone rigorous psychometric testing and received scientific support for cultural construct validity (Mills et al. 2017). One systematic review focused on the effect of acculturation for African American people (Mills et al. 2017). This review included 21 quantitative studies published between 1992 and 2012 on the relationship between acculturation and one or more of six different health behaviors (i.e., tobacco use, alcohol use, illicit drug use, risky sexual behavior, health-promoting behaviors such as physical activity, and cancer screening). Among the nine studies focused on the acculturation–smoking relationship, sample sizes ranged from 35 to 2,118 African American participants. Findings from this review indicated that less acculturated African American people had a higher prevalence of smoking than their more acculturated counterparts, which was consistent across studies testing this relationship (Klonoff and Landrine 1996, 1999; Landrine and Klonoff 1996; Guevarra et al. 2005; Fernander et al. 2008; Webb Hooper et al. 2012; Landrine and Corral 2016). Potential gender differences in the acculturation–smoking relationship were examined in the review; however, the impact of gender on acculturation and smoking for African American people was inconsistent across studies (Klonoff and Landrine 1996, 1999, 2000; Snowden and Hines 1999; Landrine and Corral 2016; Mills et al. 2017).

Measures of acculturation for African American people with rigorous psychometric support include 40–74 survey items and can take a long time to deliver in clinical and community-based research settings. The conceptualization and measurement of acculturation needs to be modernized to include the fluid nature of current intersectional identity perspectives (i.e., identifying in two or more risk groups) and the synergistic effects of identifying with other groups (e.g., people who identify as LGBTQI+) and self-identification as African American. Reducing participant burden and time to complete surveys also needs to be considered during the development of and revisions to acculturation measures. Proxy measures that represent current culture change processes for African American people and relate to the use of multiple tobacco products are warranted.

#### Acculturation and Smoking Cessation

The available evidence on the relationship between acculturation and smoking cessation among racial and ethnic groups is reviewed here. Studies on this topic have focused on Hispanic and African American people who smoke cigarettes. Disparities in access to individual-level tobacco cessation treatment for racial and ethnic groups are reviewed in the “Healthcare Environment” section of this chapter and in Chapter 7.

Among a pooled sample of 6,398 Hispanic American adults who reported smoking 100 or more cigarettes in their lifetime in the 2008–2011 Hispanic Community Health Study/Study of Latinos population-based surveys, identifying as culturally traditional was associated with better odds of quitting smoking and sustaining abstinence among Hispanic American women but not among Hispanic American men (Merzel et al. 2015). A significant age, gender, and acculturation interaction was found, namely that acculturated women younger than 40 years of age had lower odds of sustaining cessation than women older than 40 years of age who identified as culturally traditional. This survey included Hispanic American people of diverse nativity, with participants identifying as Mexican, Puerto Rican, Cuban, Central American, Dominican, or South American.

In an analysis of data from 123,574 White and Hispanic participants in the 2011–2015 National Health Interview Survey (NHIS), socioeconomic factors had a stronger association with self-reported smoking cessation (i.e., formerly smoking) than acculturation proxies (i.e., language ability, nativity, years of U.S. residency) (Castro et al. 2018). One randomized controlled trial of 271 Hispanic American adults who smoked cigarettes and sought cessation treatment found that greater acculturation (measured as language ability, years of U.S. residency, immigration status, and preferred media language) predicted higher self-reported 7-day point-prevalence abstinence rates for men (all ps <.05) but not for women (Castro et al. 2009). Research on acculturation and smoking typically has examined cross-sectional relationships between categorically independent and dependent variables (e.g., the relationship between an acculturated or traditional orientation with smoking or not smoking), which limits examination of orientation toward both a heritage and mainstream American culture. An analysis of 199 Mexican American people who spoke Spanish, smoked cigarettes, sought cessation treatment, and were enrolled in a longitudinal cohort study examined independent and interaction effects of gender and acculturation on smoking cessation, revealing that people with a strong orientation toward both Mexican and American cultures (i.e., biculturalism) were most likely to quit smoking (Castro et al. 2019). Future acculturation–smoking research could consider models that allow for an examination of the effects of biculturalism on tobacco use and cessation outcomes.

The relationship between acculturation and smoking cessation among African American people has received limited attention from the field. In a small sample (N = 140) of treatment-seeking African American people who smoked and were enrolled in a cessation pilot trial (Webb Hooper et al. 2012), acculturation, which was measured using the 47-item African American Acculturation Scale-Revised (Klonoff and Landrine 2000), predicted 7-day point-prevalence abstinence (biochemically confirmed) at the end of treatment and 3-month follow-up. Intent-to-treat analysis revealed that African American people who smoked and identified as culturally traditional had a lower likelihood of quitting smoking compared with their more acculturated counterparts. Webb Hooper and colleagues (2018) launched a randomized cessation trial that was the first study focused on African American adults who smoke cigarettes and that was powered to detect the moderating role of acculturation in smoking outcomes with biochemical feedback at 6-month follow-up. This study did not have published outcomes at the time that this report was prepared. Additional longitudinal research is needed to elucidate how acculturation helps or hurts the cessation process for Black or African American people.

#### Other Considerations for Acculturation and Smoking Research

Potential effect sizes in the acculturation–smoking relationship have been less frequently emphasized in systematic reviews on the cultural influences of smoking. One meta-analysis calculated a combined measure of effect for 12 studies (published between 1994 and 2005) and examined the acculturation and smoking relationship among Asian American people (Choi et al. 2008). In this review, the average OR for men was 0.53 (95% CI, 0.28–0.99) suggesting, according to study authors, that acculturated Asian American men were 47% less likely to smoke cigarettes than their culturally traditional counterparts. Among Asian American women, the average OR was 5.26 (95% CI, 2.75–10.05), suggesting that acculturated women were more than five times more likely to smoke than culturally traditional women. Although an average of ORs can be a potential guide of effect across studies, it is an unstandardized effect size, such that the magnitude and direction of relationships are contingent on the units of measurement in the model, which limits comparisons with other reviews that include studies with different acculturation measures. Future studies could use a standardized statistic for effect size (e.g., Cohen’s d or standardized ORs) to increase comparability of the acculturation–smoking relationship across varied measurement approaches (Cohen 1988).

The inclusion of multiple sociocultural correlates of tobacco use for racial and ethnic groups raises important measurement considerations. One study used a random, statewide sample of 2,118 U.S.-born African American adult residents of California; stratified models by gender; and included measures of acculturation, racial discrimination, and SES. The study found that the discrimination–smoking relationship failed to reach statistical significance; however, the acculturation–smoking relationship remained statistically significant for women but not for men (Landrine and Corral 2016). In the examination of independent and combined effects of acculturation, racial discrimination, SES, and gender, low acculturation was associated with smoking for women, but not for men. This finding calls for consideration of multicollinearity of discrimination and acculturation measures in models that include both sociocultural constructs and examine the relationship to smoking status.

#### Summary and Recommendations

The studies reviewed in this section document an association between acculturation and smoking among adults but not among youth. Among Asian American and Hispanic adults in the United States, men who are more acculturated are less likely to smoke, and women who are more acculturated are more likely to smoke. The literature suggests that social norms related to smoking in one’s country of origin impact the relationship between acculturation and smoking. Among African American adults, there are inconsistent findings by gender in the association between acculturation and smoking. Finally, the association between acculturation and sustained smoking cessation appears to vary by race and ethnicity.

How acculturation is measured informs which groups of people are studied and how cultural issues are framed in tobacco control research focused on racial and ethnic groups. Acculturation is not measured consistently and is often assessed using single-item measures (i.e., proxies) or time-intensive multi-item surveys. The acculturation construct can fluctuate over the lifespan, with expected shifts during child and adolescent development and during self-identity development. Self-reported responses to acculturation measures can vary when assessed in the same person at different developmental phases in their life, which suggests innovation is needed to assess acculturation using flexible and age-appropriate (or generation-appropriate) methods. Furthermore, although psychometrically rigorous, multidimensional scales of acculturation exist for Hispanic, Asian, and African American people, multidimensional acculturation surveys do not exist for use across racial and ethnic groups (Sodowsky et al. 1991; Stephenson 2000; Malcarne et al. 2006), and group-level perceptions of cultural practices, values, and social norms can change over time. Measures that can capture the influence of dynamic and intersectional cultural factors on tobacco use are needed. Furthermore, research is warranted that focuses specifically on refugee populations, including people from Middle Eastern countries where smoking is especially prevalent.

Additionally, measures of acculturation that place mainstream American practices, values, and social norms at one extreme and those of another culture at the other assume that acculturation is a linear movement in one direction that occurs along a continuum. However, acculturation can be a nonlinear process, occurring in various phases across the life course and evolving as individuals define their identities at the intersection of multiple social or cultural identities. To fully understand tobacco productrelated health disparities, future research is needed that incorporates longitudinal study designs that investigate the dynamic effect of acculturation across a person’s life course on tobacco use, especially among people with intersectional identities.

Finally, most studies on this topic have focused on cigarette smoking without incorporating measurements for noncigarette tobacco product use. Additional research is needed that examines the impact of acculturation on initiation, use, and cessation of the increasingly diverse tobacco product landscape.

## Environmental Influences

As shown in Figure 4.1, individual smoking behaviors and risks of tobacco-related health disparities are influenced by the intersection of the complex environments in which individuals live, learn, work, socialize, and access healthcare services. This section examines environmental influences on tobacco-related health disparities in several environments, including housing, school, work, and healthcare. Given the relative scarcity of literature in these areas compared with the literature on social influences, this section focuses on differences in exposure to environmental influences across disparity populations, disparities in outcomes between groups, and differences in the strength of the association between particular environmental influences and tobacco product use between demographic groups (Ward et al. 2019).

### Housing Environment

This section examines the extent to which differences in (a) exposure to secondhand tobacco smoke in the housing environment, (b) distribution of smokefree home rules, and (c) exposure to secondhand tobacco smoke in multi-unit housing exist in populations experiencing disparities.

#### Literature Review Methods

The search strategy for this review involved two PubMed searches, one on smokefree homes and one on smokefree multi-unit housing, for peer-reviewed research published between January 1, 2008, and December 31, 2021 (see Appendix 4.1 for search terms). To gain a broad understanding of the contribution of the housing environment to tobacco-related health disparities in the United States, this section focuses on results from national-level studies rather than those from studies of local-level areas.

#### Exposure to Secondhand Tobacco Smoke in Homes

Indoor public spaces have increasingly become smokefree. As a result, the home has become a primary source of exposure to secondhand tobacco smoke for both children and non-smoking adults (USDHHS 2006). An analysis of data from the 2017 and 2018 National Health and Nutrition Examination Survey (NHANES) found that 87.8% of non-smoking persons 3 years of age and older who lived with someone who smoked inside the home were exposed to secondhand tobacco smoke, as indicated by serum cotinine^1^ values of 0.05–10 nanograms/milliliter, compared with 21.4% of non-smoking persons 3 years of age and older not living with someone who smoked inside the home (Tsai et al. 2021). The data related to living with someone who smoked inside the home were not analyzed by age, race or ethnicity, or income level. In another study based on NHANES data from 2011 and 2012, Homa and colleagues (2015) found that people who rented a home and did not smoke were more likely to be exposed to secondhand tobacco smoke than were those who owned a home and did not smoke (36.8% vs. 19.0%, respectively). Furthermore, Tsai and colleagues (2021) found no significant change in the prevalence of exposure to secondhand tobacco smoke from 2011–2012 to 2017–2018 among people who rented (from 36.8% to 36.6%) and who owned (from 19.0% to 18.6%) their home.

Among U.S. middle and high school students who participated in the 2011–2019 administrations of the cross-sectional NYTS, 20.8% of non-smoking youth reported exposure to secondhand tobacco smoke in the home (Walton et al. 2020). A significantly greater proportion of non-Hispanic Black youth (24%) and non-Hispanic White youth (23%) compared with Hispanic (16%) and non-Hispanic youth of other races (18%) reported exposure to secondhand tobacco smoke in the home. Additional analysis of this sample revealed that from 2011 to 2018, exposure to secondhand tobacco smoke in the home or vehicle declined overall for youth but exposure to secondhand tobacco smoke in the home did not change for non-Hispanic Black youth, suggesting a sustained tobacco-related health disparity for this population group. A study using data from Wave 1 of the adult sample of the Population Assessment of Tobacco and Health (PATH) Study (data collection: September 2013–December 2014) (Assari and Bazargan 2019) found that, in main effects analysis, the odds of exposure to secondhand tobacco smoke at home were higher for Black adults than for White adults and higher for LGBT adults than for heterosexual adults. However, the odds of exposure to secondhand tobacco smoke at home were lower among adults with more education and those not living in poverty compared with people living in households with incomes under the federal poverty level. In an analysis of interactions by SES indicators and race or ethnicity, significant interactions between Hispanic ethnicity and SES indicators (high educational attainment and living out of poverty) suggested that the “protective” effect of higher SES against exposure to secondhand tobacco smoke was attenuated among Hispanic adults. Similar interactions between Black race and SES were not observed in this analysis (Assari and Bazargan 2019). Future studies that analyze risk of exposure to secondhand tobacco smoke by race and ethnicity and SES or structural determinants of health have the potential to elucidate intersectional issues linked to the relationship between exposure to secondhand tobacco smoke and tobacco-related health disparities.

Exposure to secondhand tobacco smoke in the home (based on self-reports) is much less common when smokefree rules are in place in that home. Using data from the 2009–2010 National Adult Tobacco Survey (NATS), King and colleagues (2013b) found that the prevalence of exposure to secondhand tobacco smoke varied considerably by the presence (or absence) of smokefree rules in the home. Overall, just 1.4% of people who did not smoke and had a smokefree rule at home were exposed to secondhand tobacco smoke in the home during the past 7 days, compared with 43.9% of people who did not smoke and did not have a smokefree rule at home. This pattern persisted across age groups, race and ethnicity, and levels of education, as shown in Table 4.1. Notably, compared with White people, a higher percentage of Black and Hispanic people but a lower percentage of Asian people were exposed to secondhand tobacco smoke in homes with and without smokefree home rules. Similarly, more high school graduates and those with a General Educational Development (GED) certificate were exposed to secondhand tobacco smoke than were those with undergraduate degrees or higher in homes with and without smokefree rules. Although the presence of smokefree home rules is associated with less exposure to secondhand tobacco smoke for some groups, the evidence points to a consistent pattern of Black people having higher exposure to second-hand tobacco smoke in the home than White people, which suggests that other factors, such as living in multiunit housing versus a single-family home, are related to exposure to secondhand tobacco smoke in the home for Black people.

Table 4.1 Percentage of nonsmoking adults who reported exposure to secondhand tobacco smoke in their homes^a^ during the previous 7 days, by smokefree rule status and selected characteristics, National Adult Tobacco Survey (NATS) 2009–2010^b^

Characteristic | Smokefree home rule (n = 91,273) (95% CI) | No smokefree home rule (n = 9,591) (95% CI) | Overall (n = 101,370)^c^ (95% CI)
Sex
Male | 1.4 (1.1–1.7) | 43.9 (40.7–47.1) | 6.6 (6.0–7.2)
Female | 1.4 (1.2–1.6) | 44.2 (41.5–46.9) | 5.5 (5.1–5.9)
Age (in years)
18–24 | 2.9 (2.0–4.0) | 63.6 (56.8–69.9) | 12.7 (11.0–14.5)
25–44 | 1.1 (0.9–1.4) | 49.7 (45.5–54.0) | 5.1 (4.6–5.7)
45–64 | 1.4 (1.1–1.7) | 41.1 (38.1–44.1) | 5.7 (5.2–6.2)
≥65 | 1.0 (0.8–1.3) | 24.0 (21.3–26.9) | 3.8 (3.4–4.2)
Race and ethnicity
Asian, non-Hispanic | 0.9 (0.4–1.7) | 29.5 (16.0–47.9) | 3.0 (1.8–5.1)
Black, non-Hispanic | 2.9 (2.0–4.1) | 58.3 (52.0–64.4) | 11.4 (10.0–13.0)
Hispanic | 1.7 (1.1–2.5) | 47.8 (38.2–57.5) | 5.3 (4.2–6.6)
Other, non-Hispanic | 3.1 (1.5–6.0) | 41.1 (30.6–52.5) | 8.4 (6.3–11.0)
White, non-Hispanic | 1.1 (0.9–1.2) | 40.9 (38.7–43.1) | 5.3 (4.9–5.6)
Education
0–12 years (no diploma) | 2.8 (2.0–4.0) | 51.2 (44.8–57.6) | 10.1 (8.7–11.8)
GED | 3.2 (1.6–6.2) | 55.5 (43.4–67.0) | 11.8 (8.7–15.9)
High school graduate | 1.6 (1.3–2.1) | 48.4 (44.6–52.2) | 8.1 (7.3–8.9)
Some college (no degree) | 1.3 (1.0–1.8) | 51.1 (46.4–55.8) | 6.5 (5.8–7.4)
Associate degree | 1.1 (0.8–1.5) | 37.8 (33.1–42.7) | 4.5 (3.9–5.1)
Undergraduate degree | 0.8 (0.6–1.1) | 26.0 (22.1–30.3) | 2.6 (2.2–3.0)
Graduate degree | 0.5 (0.4–0.8) | 22.8 (17.9–28.5) | 1.9 (1.5–2.4)
All | 1.4 (1.2–1.6) | 44.0 (41.9–46.1) | 6.0 (5.7–6.3)

Source: Adapted from Table 3 in King and colleagues (2013b).

Notes: CI = confidence interval; GED = General Educational Development.

a Defined as a response between 1 and 7 to the question, “Not counting decks, porches, or garages, during the past 7 days, on how many days did someone other than you smoke tobacco inside your home while you were at home?”

b All estimates were calculated among landline and cellular-telephone respondents.

c Includes 506 respondents whose home smoking rule was unknown.

#### Smokefree Homes and Smoking Cessation

In addition to reducing exposure to secondhand tobacco smoke, smokefree homes can support cessation. By removing social and physical environmental cues for smoking and increasing the inconvenience of smoking—for example, by requiring people to go outdoors to smoke—smokefree home rules can lead to decreased numbers of cigarettes smoked per day, delays in smoking the first cigarette after waking, and increased quit attempts and eventual cessation (Mills et al. 2009). In their study, Mills and colleagues (2009) reviewed studies that examined the impact of smokefree homes on the smoking behaviors of adults from 1990 to 2008. This review consistently found that people who currently smoke and lived in homes that had smokefree rules at baseline were more likely to have made a quit attempt within the past year and to have achieved abstinence at follow-up than those who were allowed to smoke in the home at baseline. Later, in an analysis of longitudinal data from the 2002–2003 and 2010–2011 Tobacco Use Supplement to the Current Population Survey (TUS-CPS), Vijayaraghavan and colleagues (2018) found that the prevalence of smokefree homes differed by income group over time and also accounted for 36% of the income disparity in achieving 30 or more days of continuous abstinence from tobacco use. In an earlier analysis of data from the 2006–2007 TUS-CPS, Vijayaraghavan and colleagues (2013) found that rules for smokefree homes were associated with both lower consumption of cigarettes and sustained smoking cessation among people with lower incomes who smoked compared with people with lower incomes who smoked and lived in homes without smokefree rules.

In contrast, relatively little research has been conducted on associations between smokefree homes and noncigarette tobacco product use and cessation. In a cross-sectional analysis of data from the 2010–2011 TUS-CPS, Zhang and colleagues (2016) found that having a smokefree home rule was associated with decreased odds of current use of other tobacco products, including smokeless tobacco, tobacco pipes, water pipes, and cigars (aOR = 0.80; 95% CI, 0.77–0.83). This study did not include e-cigarettes. A second study found that both full bans on vaping in the home (aOR = 0.07; 95% CI, 0.05–0.09) and partial home vaping bans (defined as vaping allowed in some places or at some times) (aOR = 0.51; 95% CI, 0.40–0.66) were associated with lower odds of current e-cigarette use compared with no restrictions on vaping in the home (Azagba et al. 2020). However, the adjusted ORs for both cross-sectional studies represent relatively small effects; longitudinal studies with larger samples are needed to examine associations between smokefree home rules and (a) quitting smoking behaviors and (b) use of noncigarette tobacco products.

Two studies examined the relationship between smokefree home interventions and quitting in racial and ethnic groups. In an analysis of pooled data across three randomized controlled trials of a brief smokefree home intervention with a sample consisting predominantly of African American (73%) and lower income (81%) people, Haardörfer and colleagues (2018) found that at the 6-month follow-up, those who had created smoke-free homes were significantly more likely to be abstinent from smoking than those who had not created smokefree homes (aOR = 6.56; 95% CI, 4.12–10.42).

In a study of 2003 California Health Interview Survey data on Asian American respondents, having smokefree rules in the home was associated with former smoking for recent immigrants and lighter smoking for long-term residents. The study’s authors speculated that acculturation influences different social norms for smoking among males in the United States compared with males in Asian countries, and these norms are associated with the smoking patterns observed in this study. The finding of increased cessation efforts in the presence of a smokefree home rule is consistent with associations found in the general population that having a smokefree home rule is associated with less exposure to cigarette smoke among Asian American people (Tong et al. 2008).

Research focused on the link between smokefree homes and smoking cessation has focused primarily on income-related disparities, but such research has rarely examined the effects of smokefree homes on cessation within or across disparate groups. Future research could examine the independent and combined effects of smokefree homes and structural determinants of health on tobacco cessation in groups most affected by tobacco-related health disparities.

#### Smokefree Homes and Smoking Behaviors Among Youth

Some research suggests that policies on smokefree homes may influence initiation of tobacco use among youth. In a review of 19 studies published between 1990 and 2010 that examined associations between smoking restrictions at home and smoking by youth, Emory and colleagues (2010) concluded that (a) the evidence was suggestive of an association between smoking restrictions at home and fewer youth initiating smoking but (b) more longitudinal research was needed to establish causality. More recent studies have not examined the potential impact of smoking restrictions at home on smoking initiation among youth by SES, race and ethnicity, or sexual orientation and gender identity (Mathur et al. 2014; O’Loughlin et al. 2014; Parks et al. 2019). Thus, it is not known whether disparities in rules for smokefree homes more broadly influence the initiation of tobacco use among youth or youth from disparity groups. Finally, more research is needed on the influence of smokefree homes on youth initiation of noncigarette tobacco products (Zhang and Pu 2016).

#### Voluntary Rules for Smokefree Homes and Risk of Exposure to Secondhand Tobacco Smoke in Multi-Unit Housing

Voluntary rules for smokefree individual units in multi-unit housing do not offer comprehensive protection from exposure to secondhand tobacco smoke for the 80 million Americans who live in this kind of housing (King et al. 2013a). Numerous studies have documented that secondhand tobacco smoke can travel through hallways and duct work into non-smoking areas (Kraev et al. 2009; King et al. 2010; Arku et al. 2015; Snyder et al. 2016). In a study that compared low-income, multi-unit residential buildings with a smokefree policy to buildings without a smokefree policy in five developments managed by the Boston Housing Authority, Russo and colleagues (2015) studied the incursion of secondhand tobacco smoke by measuring fine particulate matter (PM2.5) in conjunction with airborne nicotine concentrations and smoking (based on self-reports) in 32 households with and without people who smoked, including four pairs of adjacent units. Units in smokefree buildings had lower levels of PM2.5 compared with units in buildings with no smoke-free policy, and smoking activity in a unit was associated with higher levels of PM2.5 in adjacent units with no residents who smoked. A similarly designed study by Arku and colleagues (2015) documented variations in exposure to secondhand tobacco smoke in indoor common areas by season in six public housing buildings managed by the Boston Housing Authority. During winter months, PM2.5 and concentrations of nicotine were higher in indoor common areas in buildings that housed older adults and people with disabilities relative to buildings that housed individuals or families who were not older or had no disabilities, in buildings where smoking was permitted relative to smokefree buildings, and in high-rise buildings relative to mid- and low-rise buildings. The findings suggest that using an objective measure of exposure to second-hand tobacco smoke reveals greater exposure to PM2.5 from secondhand tobacco smoke during the winter for older people and those with disabilities who live in lowincome, multi-unit public housing.

Disparities by race and ethnicity, age, income, and region exist in the incursion of secondhand tobacco smoke into multi-unit housing. For example, findings from a 2015 analysis of the 2013–2014 NATS based on selfreported data found that among residents of multi-unit housing with rules for a smokefree home, 34.4% reported the incursion of secondhand tobacco smoke into their homes. Incursion was higher among women compared with men and among Black and Hispanic people compared with White people but it was lower for people 65 years of age and older (reference group: 18- to 64-year-olds), for those with an annual household income of $100,000 or more (reference group: <$20,000), and for those living in the Midwest or South U.S. census region (reference group: Northeast) (Nguyen et al. 2016). The findings concerning the effect of exposure to secondhand tobacco smoke in older adults than younger adults may not be directly comparable between studies. For example, estimates of exposure to secondhand tobacco smoke as reported by Arku and colleagues (2015) were measured using an objective measure of exposure to PM2.5 in conjunction with airborne nicotine particulate matter in common areas of public housing buildings, whereas Nguyen and colleagues (2016) measured exposure to secondhand tobacco smoke using self-reported incursion from a national survey. Furthermore, the study by Nguyen and colleagues (2016) included a sample of adults with higher SES. Nevertheless, both objective and self-reported measures of secondhand tobacco smoke incursion can provide a comprehensive understanding of the disparity groups that are most affected by exposure to tobacco smoke in multi-unit housing.

In a nationally representative sample of U.S. adult residents of multi-unit housing who were surveyed in 2013 (Wilson et al. 2017), among non-smoking residents with no smoking in the home for at least 3 months and a child in the home, 25.2% reported a recent incursion of second-hand tobacco smoke into their unit; 99.0% of these residents were bothered by the incursion, and among those who were bothered, 74.8% did not report the problem to a landlord or property manager. Reasons for not reporting the problem to a landlord included concerns about upsetting neighbors and retaliation. In the total analytic sample, 91.3% agreed that tenants have a right to live in a building free of tobacco smoke. Incursion was associated with living in a region other than the South, living in public versus private multi-unit housing, and living in buildings with six or more units. Incursion was not associated with race or ethnicity or level of education and income. This study highlights how easy it is for a secondhand tobacco smoke incursion to occur despite a home rule prohibiting indoor smoking. Furthermore, this study demonstrates that power imbalances exist between tenants of multi-unit housing and their property management.

Elsewhere, Licht and colleagues (2012) reported on a 2010 nationally representative sample of adults that combined two random-digit-dial surveys of residents of multi-unit housing and found that 44% of residents with a smokefree home rule experienced incursion of secondhand tobacco smoke into their unit during the past 12 months. Incursion was associated with being female, being younger than 65 years of age, and living in a building without a smokefree policy. Later, Snyder and colleagues (2016), in a review of literature about smokefree multi-unit housing published from 2001 to 2014, identified 12 studies reporting incursion of exposure to secondhand tobacco smoke, with prevalence ranging from 26% to 64%. The review assessed incursion with a range of measures, complicating comparisons across the studies. Regardless, recent national studies have generally been consistent in documenting that incursions of exposure to secondhand tobacco smoke are higher in governmentsubsidized housing (Wilson et al. 2014, 2017), suggesting a clear direction for efforts to reduce SES-related disparities in exposure to secondhand tobacco smoke among residents of multi-unit housing, as explained in the following section.

#### Smokefree Policies in Multi-Unit Housing

Given the higher rates of both smoking and exposure to secondhand tobacco smoke in lower SES populations and among residents of multi-unit housing (Wilson et al. 2014, 2017; Nguyen et al. 2016), initiatives to establish smokefree government-subsidized housing are a priority for reducing exposure to secondhand tobacco smoke in the home environment. Indeed, as of July 2018, federal government public housing in the United States is covered by smokefree policies as a result of a rule issued by the U.S. Department of Housing and Urban Development (HUD) (Federal Register 2016). This rule covers 2 million people who live in properties supported by Public Housing Agencies out of approximately 10 million people who receive housing assistance from HUD (Geller et al. 2016). Almost 90% of households receiving federal rental assistance include children or vulnerable populations (Center on Budget and Policy Priorities 2017). Chapter 7 describes what is known about (a) the impact of the HUD rule on tobacco-related disparities and (b) opportunities for addressing current gaps that leave 5–8 million residents of federal government-subsidized housing unprotected (Federal Register 2016).

Owners and property management companies that oversee privately owned affordable housing can voluntarily implement smokefree policies. In a sample of residents in market-rate and subsidized housing in six communities in 2012, 24.4% of residents in market-rate housing reported that smoking was prohibited in all areas, compared with 21.5% of residents in public or affordable housing (Gentzke et al. 2018b). Similarly, more residents of market-rate housing (82%) reported voluntary smokefree home policies than did residents of subsidized housing (69%). Elsewhere, in a 2013 survey of all affordable multiunit housing properties in North Carolina, Stein and colleagues (2015) found that 16.5% of the properties prohibited smoking in residential units. Newer properties were more likely to restrict smoking, and properties with a greater number of children per unit were less likely to restrict smoking.

#### Prevalence of Smokefree Home Rules

The 2012–2013 NATS revealed that an estimated 83.7% of adults had a smokefree home rule (Kruger et al. 2015). Among racial and ethnic groups, rates of smokefree homes were highest among Asian American people (91.5%) and lowest among African American people (75.6%); rates also varied by level of educational attainment and annual household income. Among adults with no high school diploma or a GED, 75.1% and 67.6%, respectively, reported living in a home with a smokefree rule, compared with 93.1% of adults with a graduate school degree. Similarly, 72.3% of adults with an annual household income of less than $20,000 reported having a smokefree home rule compared with 93% of adults with an annual household income of $100,000 or more.

Rules for smokefree homes also varied by sexual orientation, as an estimated 74.9% of adults identifying as lesbian, gay, and bisexual had a rule about a smokefree home, compared with 84.0% of heterosexual adults (Kruger et al. 2015). Similar associations were documented by others after analyzing (a) data from the 2010–2011 TUS-CPS and (b) data from the 2014–2015 TUS-CPS specifically for single-parent families (Zhang et al. 2015; Mai et al. 2018). Among households with one parent who smoked and a child 17 years of age and younger, rules for a smokefree home were less common in households with children whose parents were single, were non-Hispanic African American, had not completed high school, or were 40 years of age and older. Households with a child 6 years of age and older and households with incomes less than $25,000 were also less likely to have smokefree home rules (Zhang et al. 2015).

Cross-sectional studies in a variety of specific populations and communities have found similar correlates for the presence (or absence) of smokefree homes, such as smoking status, SES, and young children living in the home. For example, in their analysis of data from the Cherokee Nation American Indian Adult Tobacco Survey, Comiford and colleagues (2018) documented associations between the presence of a smokefree home rule and numerous characteristics, including being of younger age, being female, having a higher household income, having higher levels of educational attainment, not smoking, having an awareness of the harms of exposure to secondhand tobacco smoke, making a recent visit to a healthcare provider, being in good health, and having children in the home. In other studies of American Indian households, people with college degrees and people who did not smoke were more likely to live in a smokefree home than were those who smoked or did not have college degrees (Kegler and Malcoe 2002; Berg et al. 2012). In addition, in a study of Mexico- and U.S.-born Hispanic mothers, Gonzales and colleagues (2006) found that being born in the United States, current smoking status, and having other people who smoke in the home were all associated with not having a smoking rule in households with children 2–12 years of age.

Findings from the 2013–2014 NATS revealed that rules for smokefree homes were more prevalent among adults living in single-family households (86.7%) than they were among those living in multi-unit housing (80.9%) (Nguyen et al. 2016). The same study also found that (a) tobacco use was higher among adults living in multiunit housing compared with adults living in single-family housing (24.7% vs. 18.9%, respectively) and (b) use of combustible tobacco only was higher among adults living in multi-unit housing compared with adults living in single-family housing (19.8% vs. 13.6%, respectively). Elsewhere, in an analysis of NHANES data collected from 2001 to 2006, Wilson and colleagues (2011) found that among children who lived in a smokefree home, 11.6% lived in an apartment. In contrast, among children living where smoking did occur in the home, 16.7% lived in an apartment. In an analysis of cotinine levels among children living in homes where no person smoked indoors, the authors found that cotinine levels were 45% higher among children living in apartments compared with children living in single-family homes.

#### Prevalence of E-Cigarette-Free Home Rules

Few studies have examined whether the use of e-cigarettes, sometimes referred to as “vaping,” was included in rules for smokefree homes. One national study conducted in 2017 examining voluntary rules on the use of e-cigarettes inside the home found that 58.6% of adults did not allow them in the home and 23.6% were unsure of the rules (Gentzke et al. 2018a). Individuals were more likely to restrict the use of e-cigarettes in their homes if they had a college degree (compared to adults with less than a high school diploma), had a child who lived in the home, and had an annual household income of $25,000 or greater (compared with those who had an annual household income of less than $15,000). By race and ethnicity, African American adults were less likely than White adults to restrict the use of e-cigarettes in their homes. Additionally, adults who currently used or who had previously used e-cigarettes and who currently used or who previously used cigarettes were less likely than adults who never used e-cigarettes and cigarettes, respectively, to restrict the use of e-cigarettes in their homes (Gentzke et al. 2018a).

A study using data from the 2018 TUS-CPS found that 89% of U.S. respondents 16 years of age and older indicated that no one was allowed to vape anywhere in their home, but only 32% of homes of individuals who currently used e-cigarettes had such restrictions (Azagba et al. 2020). Similarly, Li and colleagues (2020) found that, in Wave 3 of the PATH Study (2015–2016), 90% of people who never used e-cigarettes or smoked cigarettes had a rule prohibiting vaping in their homes, followed by people who formerly smoked cigarettes (86%), currently used e-cigarettes but never smoked cigarettes (56%), currently smoked cigarettes (54%), currently used both cigarettes and e-cigarettes (25%), and currently used e-cigarettes and formerly smoked cigarettes (21%). However, these two studies did not provide information on the presence or absence of home vaping rules by race and ethnicity or SES.

#### Housing Summary

Significant disparities in exposure to secondhand tobacco smoke in the home exist by race and ethnicity, SES, home ownership status, the presence or absence of smokefree policies in multi-unit housing, and whether voluntary rules for smokefree homes are in place. Smokefree home rules are differentially distributed across populations and are less common in Black or African American and lower SES households than in White and higher SES households, respectively. Multiple studies suggest that rules for smokefree homes vary by the sexual orientation and gender identity of the household members, composition of the household, presence of children, race and ethnicity, SES, and multi-unit housing. Despite an association between smokefree rules in the home and smoking among youth, few studies have examined potential disparities in this relationship among youth from diverse backgrounds.

The evidence suggests that maintaining smokefree homes reduces exposure to secondhand tobacco smoke, decreases tobacco product use, and aids in smoking cessation. However, because many of the studies in this section used cross-sectional data, future research is warranted that incorporates longitudinal study designs to determine the direction and temporality of the association between smokefree and e-cigarette-free rules in the home and cessation of tobacco product use.

Tobacco-related health disparities by SES are further compounded by the movement of secondhand tobacco smoke throughout multi-unit housing. In fact, people who live in multi-unit housing experience disparities in exposure to secondhand tobacco smoke by age, disability status, race and ethnicity, level of income, gender status, and geographic region. Inequitable smokefree protections for people living in public or multi-unit housing can exacerbate disparities in exposure to secondhand tobacco smoke. Given this evidence, public health practitioners could partner with community members to increase smokefree and e-cigarette-free protections in homes—for example, through focused outreach to multiunit housing providers about the health and financial benefits of smokefree housing—and could couple such efforts by promoting evidence-based cessation approaches among residents (CDC 2015). Future studies can identify best practices for advancing equitable smokefree protections for residents of multi-unit housing.

In summary, the prevalence of smokefree and e-cigarette-free home rules can differ by race and ethnicity, education level, income level, and sexual orientation of residents and by housing type. The known dangers of exposure to secondhand tobacco smoke, coupled with the fact that aerosol from e-cigarettes can expose bystanders to toxicants (USDHHS 2016), warrants additional efforts to increase the adoption of smokefree and vape-free homes.

### School Environment

Adolescents spend the majority of their waking hours in school, where they are situated in a unique physical environment that facilitates increased peer interactions under relatively limited adult supervision (Rutter 1982). The school environment may be defined broadly as what students are offered by schools in terms of the quality of teaching and mentoring, general guidance, teacher–student relationships, policies, services, systems of reward and punishment, and physical surroundings (Bonell et al. 2016). The school environment is a strong predictor of health risk behaviors, including the use of tobacco and other substances, among adolescents (Fletcher and Bonell 2013). In addition, the school environment influences tobacco use by interacting with such sociodemographic factors as race and ethnicity, SES, sex, and sexual orientation and gender identity (Bonell et al. 2016; Coulter et al. 2018). Thus, understanding how the school environment and sociodemographic factors interact to affect diverse groups of youth is warranted. This section focuses on the middle and high school environment and tobacco-related health disparities relevant to youth between 13 and 18 years of age.

The 2012 Surgeon General’s report concluded that “socioeconomic factors and educational attainment influence the development of youth smoking behavior. The adolescents most likely to begin to use tobacco and progress to regular use are those who have lower academic achievement” (USDHHS 2012, p. 10). This section goes beyond the 2012 Surgeon General’s report to provide evidence of how the school environment more broadly and differentially influences the risk of tobacco use among specific youth populations.

#### Literature Review Methods

This review is based on a systematic literature search conducted across the PubMed, PsycINFO, and ERIC databases. These databases were selected because they are the ones most likely to index journals that publish peerreviewed research on school-based tobacco and substance use among adolescents. See Appendix 4.1 for search terms. This section includes peer-reviewed publications, based on search criteria, in the literature from January 1, 2008, to December 31, 2021. Where noted, differences by gender are also provided, but neither boys nor girls were designated as a disparity population. This review does not include studies focused on the role of school tobacco policies in reducing exposure to secondhand tobacco smoke or e-cigarette aerosol across disparity populations.

#### Influence of the School Environment on Adolescent Health Behaviors, Including Tobacco Use

This section describes the mechanisms through which the school environment influences adolescent health behaviors, including tobacco use. Based on reviews of both empirical and qualitative studies, Bonell and colleagues (2013, 2016) developed a conceptual model that integrates several ways in which the school environment may influence tobacco use and other behaviors among adolescents. Illustrated in Figure 4.2, this model postulates that a positive school environment promotes better bonding with a school, which helps students learn better self-control skills, internalize prohealth norms and attitudes, and affiliate with prosocial peers (i.e., exerting a positive or helpful influence). These outcomes, in turn, protect students from engaging in health risk behaviors, including but not limited to tobacco use. The school environment may directly affect health risk behaviors, such as tobacco use, through health education programs or by enforcing tobacco-free campus policies (Bonell et al. 2016) and practices (e.g., through increased supervision) (Shackleton et al. 2016). The school environment may also influence tobacco use indirectly by creating feelings of school connectedness or attachment. This model may be extended to understand the influence of school environment on tobacco use and the other health risk behaviors of youth who are members of populations that are disproportionately affected by tobacco-related health disparities.

According to data from the 2021 Youth Risk Behavior Survey, 61.5% of U.S. high school students reported feeling connected to others at school. Feelings of school connectedness were lower among Black or African American students (53.9%) and Hispanic or Latino students (59.8%) than were such feelings among White students (65.2%) (Wilkins et al. 2023). School connectedness or school attachment reflects students’ pride in their school, their feelings of bonding with the school and teachers, and their sense of school as a community (Shackleton et al. 2016). A demonstrated link exists between a school environment that promotes school bonding and the development among students of self-regulation skills and affiliation with prosocial peers (Markham and Aveyard 2003). The term self-regulation refers to the ability to regulate one’s feelings, thoughts, and behaviors (Wills et al. 2013). Schools can help students develop effective self-regulation skills and prosocial affiliation through guidance and instruction and by providing opportunities to engage in activities that require teamwork, discipline, respect for one another, and respect for conventions and institutions (Hawkins and Weis 1985; Markham and Aveyard 2003). Research has shown that poor self-regulation and deviant peer affiliation (i.e., selecting friends who engage in problem behaviors) are two of the strongest predictors of substance use by adolescents (Wills et al. 2013).

Figure 4.2 Conceptual model of how school environment influences student behavior

Illustration of the conceptual model of how the school environment influences student behavior, as described in the narrative text.

Source: Adapted from Bonell and colleagues (2013, 2016).

Among younger African American adolescents in particular, greater school bonding has been found to be associated with better life skills (Booker 2006). Both the quality of teacher support and of peer relations appears to shape school bonding among African American children and early adolescents (Booker 2006). Additionally, Dotterer and colleagues (2009) found that, among African American youth, perceived discrimination was negatively associated with school self-esteem and school bonding. Experiencing racial or ethnic discrimination at school is associated with negative outcomes for youth who are African American (Thompson and Gregory 2011; Ispa-Landa 2013; Leath et al. 2019).

In addition, school environment can play a role in the development of factors that may be mediators of substance use among students from racial and ethnic groups, such as life skills. For example, in a study of elementary school-aged adolescents of African American or Puerto Rican descent, Brook and colleagues (2006) found that a poorer school environment—measured in terms of academic motivation, school pride, and learning environment—was associated with greater rebellious, devianceprone behaviors among adolescents. The association was significant even after accounting for the effects of the child’s personality characteristics, parent characteristics (including substance use), ethnic identification and perceived racial or ethnic discrimination, and peer affiliation. School environment was the only variable that significantly explained the variance in rebellious behaviors after adjusting for the child’s personality attributes.

Overall, the influence of the school environment on tobacco use behavior and tobacco-related norms among youth from groups that are disproportionately affected by tobacco-related health disparities needs to be understood in terms of the intermediary roles played by the school’s organization and physical environment, deviant peer affiliation, and tobacco control programs and policies in both the school and community context. The next section discusses research on the influence of school environment on tobacco use among students from racial and ethnic groups.

#### School Environment, Students from Minoritized Racial and Ethnic Groups, and Tobacco Use

Research examining the influence of the school environment on tobacco use or its antecedents among adolescents from racial and ethnic groups has focused primarily on African American and Hispanic youth (Robinson et al. 2003; Brook et al. 2006; Corona et al. 2009; Zhen-Duan and Taylor 2014; Dornbusch et al. 2016; Bersamin et al. 2017). These studies have primarily examined attachment to school, commitment to school, and academic orientation as variables that influence tobacco use (e.g., Gerrard et al. 2005; Brook et al. 2006; Zhen-Duan and Taylor 2014; Dornbusch et al. 2016). In a prospective study of African American preadolescents, Gerrard and colleagues (2005) found that greater school bonding (assessed as “academic orientation”) at baseline was associated with lower likelihood of cigarette smoking initiation 2 years later and contributed to beliefs and attitudes that smoking is not glamorous or attractive. In another study, Dornbusch and colleagues (2016) found that school connectedness (assessed in terms of a student’s sense of belonging to the school and of having strong relationships with teachers and classmates) was a protective factor against tobacco use among African American and Hispanic youth. Similarly, in the 2011 Healthy Kids Colorado Survey, Yang and Anyon (2016) found that school bonding mediated the relationship between race and ethnicity and cigarette smoking for all groups. However, compared with White youth, Black, multiracial, and Latino youth showed significantly lower levels of school bonding while Asian students showed higher levels of school bonding (Yang and Anyon 2016). Among a sample of Hispanic youth, positive school climate and bonding were associated with a perception that few peers engage in substance use, which, in turn, was associated with a lower likelihood of substance use, including tobacco (Bacio et al. 2015). Similarly, a study of Asian American youth found that a positive school climate had a protective effect on tobacco use intensity (Ryabov 2015). Lack of school attachment and commitment may also contribute to tobacco and other substance use as a form of anti-authority, anti-convention, or anti-school sentiment (Fletcher and Bonell 2013). Alternatively, tobacco and substance use may be the outward expression of anti-school cultural beliefs among adolescents (Bonell et al. 2019).

Higher perceived school bonding is also associated with proximal protective factors—such as higher academic achievement and better mental health—against tobacco and other substance use among youth from minoritized racial and ethnic groups (Stewart 2007; Corona et al. 2009). For example, among Hispanic adolescents, having better relationships with adults at school was a protective factor against poor mental health outcomes (Hall et al. 2018a). In general, it appears that school environments that foster healthy emotional engagement with a school, such as better bonding between peers and between teachers and students, are likely to protect youth, including youth from racial and ethnic groups, from health risk behaviors such as tobacco use (Li and Lerner 2011; Kim and Chun 2018). Additionally, a school environment that provides opportunities for positive behavioral engagement, such as participation in extracurricular activities, may be protective against high-risk behaviors, including tobacco use among adolescents from racial and ethnic groups (Corona et al. 2009; Li and Lerner 2011; Diaz 2016). In fact, higher participation in youth sports has been hypothesized to be one of the reasons for delayed onset of cigarette smoking among African American youth (Garrett et al. 2016). A review of studies of participation in high school and college sports found that 14 out of 15 studies that assessed cigarette smoking found an inverse relationship between sports participation and cigarette use; however, this review did not examine racial and ethnic differences in these relationships (Lisha and Sussman 2010). It is also important to note that engaging in extracurricular activities, especially academic activities (e.g., honor system, student newspaper) and athletics, is protective against deviant behavior and maladjustment among youth from racial and ethnic groups and White youth (Fredricks and Eccles 2010; Latimore et al. 2017). It is possible that physical activity reinforces a belief or attitude that smoking negatively affects breathing during exertion, which can hinder athletic performance and reduce the ability to compete with peers, and which might be a mechanism through which youth participation in athletics discourages tobacco initiation or regular use. Future studies could elucidate the mechanisms that reinforce the protective effects of youth athletics against smoking and other tobacco use. Unfortunately, research shows that participation in extracurricular activities is lower among adolescents from minoritized racial and ethnic groups than White youth (Brown and Evans 2002; Darling et al. 2005; Markstrom et al. 2005; Li and Lerner 2011; Peguero 2011).

Overall, some evidence suggests that school bonding—alternatively characterized as school attachment, school belongingness, and school connectedness—is an aspect of the school environment that affects tobacco use among youth who are members of racial and ethnic groups. At least one study (Gerrard et al. 2005) prospectively demonstrated the association between African American children feeling more connected to their schools and having negative beliefs about smoking, being less willing to smoke, and eventually reporting less smoking—an effect that held after controlling for neighborhood risk factors, family SES, and risk-taking tendencies. However, another study found that youth from families with lower income levels as well as African American and Latino youth were more likely to follow less favorable trajectories of emotional and behavioral engagement with school during a 4-year evaluation period compared with youth from families with higher income levels and European American youth; these types of trajectories were associated with greater rates of substance use including cigarette and smokeless tobacco use (Li and Lerner 2011).

Research shows that higher perceived racial or ethnic discrimination and bullying in school are also likely to result in greater substance use among adolescents from minoritized populations (Stone and Han 2005; Unnever et al. 2015). Feeling marginalized because of one’s race or ethnicity is an important source of stress for youth (Benner and Wang 2015), which may promote tobacco use directly (e.g., through methods of coping) (Wills 1986) or indirectly through reduced school attachment (Dotterer et al. 2009; Benner and Wang 2015; Lorenzo-Blanco et al. 2016). Lorenzo-Blanco and colleagues (2016) found that, among a sample of Hispanic youth, odds of current cigarette smoking were highest among youth who experienced the highest levels of perceived ethnic discrimination and the lowest level of protective factors (i.e., low perceived school safety and social support) as well as youth who experienced very high bullying victimization in school and very high perceived ethnic discrimination compared with youth who had the highest protective and lowest risk factors (i.e., low perceived discrimination, low bullying victimization, and high perceived school safety and social support).

Although young people may use tobacco products in an attempt to cope with stressors, nicotine dependence is itself a source of stress given the symptoms of anxiety, depression, and irritability that can occur during withdrawal (USDHHS 2014). Efforts to promote healthy coping strategies among youth and to simultaneously eliminate sources of stress—such as bullying, discrimination, and institutional racism—are warranted to promote health equity.

#### School Environment, Adolescent Sexual Orientation and Gender Identity, and Tobacco Use

The 2019 U.S. National School Climate Survey indicated that a majority of students in U.S. middle or high schools who identify as LGBTQ experience harassment and discrimination (Kosciw et al. 2020). Among students who are LGBTQ, 86.3% reported experiencing harassment or assault based on sexual orientation or gender expression at school, and 59.1% reported experiencing discrimination in school because of their sexuality. In addition, 52.4% reported having encountered negative remarks about their sexuality from school staff, and 66.7% reporting hearing negative remarks about gender expression from school staff. The survey also found that LGBTQ students who experienced higher levels of harassment and discrimination were significantly more likely to report lower levels of self-esteem and higher levels of depression. For students from minoritized sexual orientation and gender identity groups, the U.S. school environment is associated with major stressors that foster a hostile environment and psychological distress (Gebrekristos 2012).

Harassment based on sexual orientation is a major stressor associated with disparities in tobacco use among students from sexual orientation and gender identity groups compared with heterosexual and cisgender students (cisgender denotes gender identity that coincides with the sex that a person was assigned at birth) (Day et al. 2017; Coulter et al. 2018). Based on their analysis of data from the 2013–2014 California Healthy Kids Survey, which used an analytic sample of 316,766 students who were in Grades 7, 9, and 11 in California, Coulter and colleagues (2018) found that reported experiences of gender- or sexuality-based harassment were associated with higher odds of past-month smoking or e-cigarette use among LGBTQ students compared to their heterosexual counterparts. Huebner and colleagues (2015) found that, in a sample of LGBT adolescents, anti-LGBT victimization in schools was associated with greater smoking frequency and this relationship was mediated through greater association with deviant peers but not with level of school bonding.

Reduced school commitment and attachment also exacerbate tobacco use disparities among transgender adolescents (Hatchel and Marx 2018). Harassment and discrimination negatively affect senses of school belonging among students who identify as LGBTQ (Kosciw et al. 2020). Conversely, positive senses of school belonging may be an important factor for reducing substance use, including tobacco use, among transgender youth (Hatchel and Marx 2018). Analyzing data from the National Longitudinal Study of Adolescent Health (Add Health) study, Russell and colleagues (2001) found that poor relationships with teachers were associated with problems in school among youth from sexual orientation and gender identity groups (e.g., not getting along with peers, not doing homework). Thus, any strategy to address tobacco use among youth from minoritized sexual orientation and gender identity groups in the school setting needs to address the widespread discrimination and marginalization experienced by this population in school.

#### School Environment, Socioeconomic Factors, Rurality, and Tobacco Use

The 2012 Surgeon General’s report on tobacco use among youth and young adults concludes that “[t]he prevalence of cigarette smoking is also highest among lower socioeconomic status youth” (USDHHS 2012, p. 9) and that “[s]ocioeconomic factors and educational attainment influence the development of youth smoking behavior” (USDHHS 2012, p. 10). However, how the school environment affects the development of these types of disparities by SES is not specifically discussed in the 2012 Surgeon General’s report. Beyond the influence of individual SES, smoking among youth is also influenced by school SES (i.e., aggregated measures of the socioeconomic status of students in particular schools). A national study found that odds of cigarette smoking among girls was related to attending schools of lower versus higher SES, but these relationships were stronger for American Indian and White girls than for girls of other racial and ethnic backgrounds (Wallace et al. 2009). In another study on school environment and SES factors, Wong and colleagues (2014) conducted a natural experiment to examine whether youth who attended high-performing schools in lower income neighborhoods were less likely than youth who did not attend such schools to engage in risky health behaviors. The study compared lower income youth who had been randomly selected to attend high-performing public charter schools in Los Angeles with lower income youth who had applied for but were not selected to attend such schools. This study found that, after controlling for individual student SES, exposure to a high-performing school environment was associated with increased test scores, but the study did not find differences in past-30-day cigarette use, suggesting that changing schools may not modify the risk of tobacco use among lower income students.

Isolation and rurality also influence tobacco use among adolescents. As described in Chapter 2 of the current report, the prevalence tobacco use, including cigarettes and smokeless tobacco products, is higher in rural areas than it is in urban areas in the United States. Furthermore, the prevalence of smokeless tobacco product use is higher among men than it is among women. A cross-sectional study examined tobacco use among youth in different rural contexts (e.g., communities of less than 50,000 people and youth living on farms, in the country but not on farms, or in towns) and included an analytic sample of 18,767 adolescents enrolled in 6th, 8th, 10th, and 12th grades at public schools (Rhew et al. 2011). Odds of lifetime and past-30-day smokeless tobacco use were greater among high school students living in the country or on a farm compared with their counterparts living in towns; however, odds of lifetime and past-30-day cigarette smoking did not differ significantly by residential context. The study also found that rural high school youth living in the country or on farms were exposed to fewer school protective factors (i.e., opportunities and rewards for prosocial involvement) and higher school risk factors (i.e., academic failure and low commitment to school) versus youth living in towns. Additionally, after adjusting for parental education, school risk factors were strongly associated with greater odds of lifetime and current smokeless tobacco use among high school and middle school students across rural contexts, and school protective factors were associated with lower risk of lifetime and current smokeless tobacco use among town residents but not among students living on farms. Although indirectly related to schools, more recent work has used alternative measures of geographic isolation. For example, Blank and colleagues (2022) used an isolation scale that measures access to health-related resources by ZIP code to evaluate associations between geographic isolation and patterns of tobacco use in a sample of high school students from north-central Appalachia. Adolescents with higher isolation scores were more likely to engage in polytobacco product use and experiment with cigarettes or e-cigarettes. Chapter 5 discusses targeted marketing by the tobacco industry, including such marketing targeted at rural populations.

#### Youth Exposure to Tobacco Prevention Policies and Programs in Schools

Another aspect of the school environment that is likely to influence adolescents’ tobacco use behavior is school-level tobacco-free campus policies and tobacco prevention programs (Bonell et al. 2016). In a systematic review of 31 studies that examined the effects of schoollevel policies on students’ smoking behavior, Galanti and colleagues (2014) found that comprehensive smoking bans, clear rules, strict policy enforcement, and the availability of prevention and cessation support were all associated with lower prevalence of smoking among students. However, the authors could not draw strong causal inferences because most studies in their review were qualitative or cross-sectional designs. Although most of the studies were based in the United States and Canada, the proportion of adolescents from minoritized racial and ethnic groups across study samples was unclear. One review highlighted the mechanisms through which successful school-level policies may affect student smoking behavior (Schreuders et al. 2017). This study found that adolescent smoking decreased if school policies made them (1) feel that they would be sanctioned for smoking, (2) feel less pressure to conform to attitudes and behaviors of their pro-smoking peers, and (3) feel that opportunities were provided to help with quitting smoking or remaining abstinent. However, only a few of the identified U.S. studies examined whether exposure to schoollevel tobacco policies differed across disparity groups or whether the effectiveness of such policies differed among youth from disparity populations.

One national-level study found that local tobacco prevention programs were less prevalent in schools where the student population was predominantly African American or Hispanic compared with schools where the student population was predominantly White (Kumar et al. 2013). Such programs were also less prevalent in schools of lower SES with higher percentages of students on free or reduced-price lunch than in more socioeconomically advantaged schools.

Further examination of the relationships between individual factors (i.e., age and Black or other versus nonLatino White) and neighborhood factors on racial disparities in smoking or receipt of youth tobacco prevention education in schools occurred in a 2010 analysis of student data from the 2005–2006 Virginia Youth Tobacco Survey (Kaestle and Wiles 2010). For this analysis, neighborhood characteristics were assessed by a neighborhood socioeconomic disadvantage variable, which included but was not limited to measures of poverty, unemployment, education, racial composition, and urban status. A neighborhood’s urban status, proportion of Black residents, and social disorganization factors (e.g., measured in the study as single-parent family status, homes with no vehicle, and owner-occupied housing) were not associated with youth smoking or receipt of tobacco prevention education. Overall, adolescents living in socioeconomically disadvantaged neighborhoods had a significantly higher relative risk of light, medium, or heavy cigarette smoking than did youth from more advantaged neighborhoods. However, by race and ethnicity, Black adolescents had a significantly lower relative risk of heavy smoking than White adolescents. Adolescents in socioeconomically disadvantaged neighborhoods also had significantly lower odds of having received tobacco prevention education in school. This study shows how socioeconomic disadvantage at the neighborhood level can influence adolescent smoking and low receipt of tobacco prevention education in schools. The intersection of SES and race and ethnicity deserves further study in relation to other tobacco product use and other social determinants of health.

In another study conducted in Kentucky schools (Hahn et al. 2005), having a comprehensive tobacco-free campus and providing cessation resources in school were more common in schools in urban areas than in schools in nonurban areas. This finding suggests a potential need to increase tobacco prevention in schools located in rural communities.

The literature on the associations between school environment and tobacco use suggests that a lack of tobacco control policies in schools, or weak enforcement of such policies, is associated with tobacco use and worse SES-related disparities, although the evidence for policy comprehensiveness is mixed (Bonell et al. 2013). For instance, in Waves I–III of the Add Health cohort study, exposure to comprehensive school tobacco control policies affecting both students and staff was associated with lower odds of ever using tobacco among students, but exposure to policies that only addressed student smoking was not significantly associated with reduced odds of ever use in this age group (Jayawardhana et al. 2019). Adams and colleagues (2009) found that active enforcement of a school tobacco policy was associated with lower odds of tobacco use among students but no difference was seen based on the comprehensiveness of the policy. Boris and colleagues (2009) found no overall difference in current smoking among Louisiana ninth graders entering high schools with either a comprehensive smoking policy or a policy allowing for staff smoking in restricted areas. However, African American youth had higher odds of smoking if attending a school with a comprehensive tobacco-free policy compared to a school with a restricted smoking policy, and White youth showed no differences in prevalence of smoking based on policy type at school. The authors of this study speculated that the findings might represent a boomerang effect (i.e., increased smoking rates for African American students in schools with a comprehensive smokefree policy). Although the findings appear to be counterintuitive, it has been noted that Black youth tend to feel less connected to school than White youth (Yang and Anyon 2016). This may suggest that school-based tobacco policies could have less influence over tobacco use among the members of this racial and ethnic group compared to other social or environmental factors (i.e., tobacco use among peers who are Black, exposure to tobacco marketing).

In general, studies have rarely examined the effects of school-based tobacco control policies on tobacco use among students who are members of minoritized racial and ethnic groups relative to White students, students from sexual orientation and gender identity groups compared with heterosexual students, or lower versus higher SES students. Findings on the impact of perceived strictness of a policy appear mixed, potentially due to differences in study design. In a representative sample of 8th and 11th graders in Oregon, attending a school in which students perceived the smoking policy to be strictly enforced was associated with lower odds of any cigarette smoking, daily smoking, smoking on school property, and smoking if offered a cigarette by a best friend (Lipperman-Kreda et al. 2009). In contrast, a multilevel analysis of the impact of school-level tobacco policies on the prevalence of smoking among a representative sample of youth in Michigan found that the stringency of enforcement of a tobacco-free school policy was not significantly associated with current smoking after accounting for individual variables; however, all schools included in the study had a comprehensive tobacco-free school policy (Paek et al. 2013).

On the other hand, studies consistently demonstrate that the presence of health centers in schools that serve students of lower SES, students from sexual orientation and gender identity groups, and students from racial and ethnic groups, especially African American students, is a protective factor for multiple health problems, including tobacco use (Robinson et al. 2003; Knopf et al. 2016; Bersamin et al. 2017; Zhang et al. 2020). In 2015, the Community Preventive Services Task Force published a report based on a systematic review of 46 studies that evaluated onsite clinics serving urban, lower income, and high school students from racial and ethnic groups. The review found that having a school-based health center was associated with improved educational outcomes (e.g., higher grade point average, less suspensions) and health-related outcomes (e.g., lower substance use) in low-income communities (Knopf et al. 2016). However, the United States has a paucity of available school-based health centers. CDC estimated that, based on a representative sample of U.S. public and private school districts in 2016, the percentage of schools that had a school-based health center ranged from 6.0 to 52.0% across states (median: 21.5%) and from 5.6 to 56.6% across large urban school districts (median: 30.0%) (Brener et al. 2017). Nevertheless, the benefits of school-based health centers extend beyond reduced tobacco use among youth from racial and ethnic groups; their presence in schools serving youth from lower income, urban communities can be a conduit for improving health education, substance use prevention, and receipt of needed physical and mental health services, thus advancing health equity for students from racial and ethnic groups (Knopf et al. 2016).

E-cigarettes and emerging tobacco products have unveiled a fresh set of challenges for schools. Several studies have found that e-cigarette use is common on school grounds. For example, in the 2019 NYTS, 64% of U.S. youth reported noticing youth use of e-cigarettes at school (Dai 2021). Among Connecticut high school students, 45% of students who currently used e-cigarettes reported that they used their product in school with most use reported in school bathrooms (Jackson et al. 2020). In addition, studies have also found that it may be difficult for teachers and school administrators to distinguish some pod-based e-cigarette devices, such as JUUL e-cigarettes, from day-to-day electronic objects, such as flash drives (Schillo et al. 2020). These factors may complicate the enforcement of antitobacco policies in schools. Nonetheless, Nicksic and colleagues (2018) showed that having a school policy on e-cigarettes, such as comprehensive bans and restrictions on their use, is correlated with a lower likelihood of students using these devices. Notably, this research was based on a sample from Texas of which more than half were Hispanic youth. However, to date, little information is available that examines how school policies restricting e-cigarette use may or may not influence tobacco-related health disparities.

Multilevel study designs can elucidate the changing influence of schools over the course of the youth e-cigarette epidemic. Lippert and colleagues (2019) used multilevel modeling to find that school-level associations with student vaping decreased as e-cigarettes became more commonplace nationwide, even after controlling for student characteristics and exposure to tobacco use among friends and family members. Thus, although school contexts are still consequential, particularly during early stages of the youth e-cigarette epidemic, the influence of the school setting on student behaviors may shift in response to concurrent changes in broader health practices, culture, and policy in society. These findings have implications for diverse groups of youth, given that e-cigarettes were most commonly used initially by White male students but, as of 2021, were the most commonly used tobacco product among youth across genders and across all other racial and ethnic groups, as measured in the NYTS (Gentzke et al. 2022).

Although limited evidence exists regarding effective cessation interventions for youth in general (Fiore et al. 2008; U.S. Preventive Services Task Force 2020), researchers have been examining for decades the usefulness of giving youth access to smoking cessation services through school-based health centers (Kisker and Brown 1996; Price et al. 2003). However, little evidence is available on how such services are being made available to racially and ethnically diverse youth, students with lower SES, and students from sexual orientation and gender identity groups who use tobacco products. With the rise in the prevalence of e-cigarette use among adolescents, school-based health centers might play an important role in treating adolescents’ addiction to nicotine through, for example, direct delivery of cessation services and connection to health system- or community-based cessation resources. Among schools in their sample of 168 public middle and high schools in Oregon, Paschall and Bersamin (2018) found that e-cigarette use increased sharply over time in schools without a health center compared to schools with a health center. Earlier, however, Price and colleagues (2003) noted that schools often struggle with establishing or maintaining health centers or smoking cessation treatment services within the schools themselves because of a lack of financial resources and personnel who are qualified to provide such services. Promoting the use of schoolbased health centers, especially in lower income schools and schools that serve students from racial and ethnic groups, may be an important strategy to reduce tobacco-related disparities (Darling-Hammond 2013). Beyond this approach, however, school-based tobacco prevention programs might benefit from a more person-centered—versus a demographic characteristic-centered—ecological approach and from addressing such issues as perceived discrimination (Unger 2015) and victimization, which influence school climate and school bonding.

The limited existing research suggests that comprehensive tobacco-free campus policies are especially important in socioeconomically disadvantaged communities, as such policies may protect youth at highest risk of smoking. Additionally, providing prevention education and cessation services through school-based health centers may serve as a protective factor against smoking among students who are members of diverse racial and ethnic groups and students from sexual orientation and gender identity groups. Still, longitudinal, cross-sectional, or experimental research rarely documents differences in exposure to such policies by race and ethnicity or SES. Additionally, whether the presence of such policies reduces noncigarette tobacco product use is unclear, as are the effects on reducing tobacco-related health disparities.

#### School Environment Summary

This section highlighted the importance of the school environment as a determinant of tobacco product use among youth from populations that are disproportionately affected by tobacco-related health disparities. Experiencing higher levels of school connectedness may be protective against tobacco product use among African American and Hispanic youth, but these students can experience lower levels of school bonding compared with students of other racial groups, such as Asian youth. Although the mechanisms explaining these relationships are not well understood, a few studies suggest that school engagement, such as participation in team sports or extracurricular activities, may reduce the likelihood of smoking among certain racial and ethnic groups of youth.

Evidence also suggests that youth from certain racial and ethnic groups are likely to show less engagement with school. Factors that may discourage these youth from forming better bonds with schools include social stigma and perceived discrimination. Data from the studies in this review suggest that adolescents from some racial and ethnic populations experience higher levels of discrimination and bullying than do White youth, which may ultimately impact disparities in tobacco product use.

Similarly, associations may exist between smoking and harassment and victimization experienced in schools on the basis of sexual orientation and gender identity and between smoking and e-cigarette use among adolescents who are LGBTQI+. Lower levels of school commitment and attachment might modify these relationships. Furthermore, school SES and individual race and ethnicity could impart multilevel interacting effects on smoking among adolescents. Given that many adolescents have intersectional identities and diverse experiences, future research could utilize additional multilevel studies to examine the interaction between school-, neighborhood-, and individual-level characteristics and tobacco product initiation and use.

Exposure to school-level tobacco control policies and programs constitutes another environmental factor that may influence differences in the use of tobacco products among youth. Having tobacco prevention programs and policies in schools is associated with a lower prevalence of smoking among adolescents. However, not all students have access to these policies and programs. In fact, there are disparities in the racial and ethnic, socioeconomic, and geographic characteristics of the schools that implement antitobacco policies and provide tobacco prevention and smoking cessation services. Because the prevalent use of e-cigarettes among youth can pose challenges for the enforcement of comprehensive tobaccofree policies in schools, it is important to examine how these policies are implemented in diverse school environments. Chapter 7 addresses approaches for designing effective school-based tobacco-free programs for youth from various racial and ethnic groups. However, additional research is needed to investigate how the unequal access to these policies, programs, and treatment services in schools can contribute to disparities in tobacco product initiation and use among youth.

### Work Environment

The work environment influences health through physical, psychological, economic, and social mechanisms. These mechanisms include both positive aspects of the work environment, such as social support for wellness resources, and negative aspects, such as exposure to toxicants and psychosocial stress (Okechukwu et al. 2010). Positive working conditions contribute to improvements in multiple health outcomes (Schnall et al. 2009; Marmot and Bell 2010; Pfeffer 2018), including tobacco use patterns (Sorensen et al. 2004; Albertsen et al. 2006). A health-promoting workplace offers resources that support quitting, including rewards, control over decision making, and social support (NCI 2017a). However, as documented in NCI Tobacco Control Monograph 22 (NCI 2017a), working conditions may create stressors that contribute to increased tobacco use and barriers to quitting (Haenszel et al. 1956; Sterling and Weinkam 1976; Nelson et al. 1994; Leigh 1996; Giovino et al. 2000; Lee et al. 2007; Sorensen and Barbeau 2012). Studies consistently demonstrate that exposure to hazardous factors in the workplace occurs differentially across demographic subgroups, such as those defined by age, sex, race and ethnicity, educational attainment, or sexual orientation (Loomis and Richardson 1998; Murray 2003; Berdahl 2008; Clougherty et al. 2010; Steege et al. 2014), and thus workplace factors have the potential to influence tobacco-related health disparities.

The 1985 Surgeon General’s report, The Health Consequences of Smoking: Cancer and Chronic Lung Disease in the Workplace, examined the combined effects of occupational exposures and cigarette smoking on tobacco-related diseases (USDHHS 1985). The report identified disparities in cigarette smoking by race and ethnicity and sex, even after accounting for occupation or occupational classification.

Chapter 8 (“Occupation, the Work Environment, and Tobacco-Related Health Disparities”) in NCI Tobacco Control Monograph 22 (NCI 2017b) contains information and conclusions that are highly relevant to this section:

“More than 30 years after the [1985 Surgeon General] report’s publication, significant disparities in tobacco use persist across the tobacco use continuum by occupation. Blue-collar and service workers are more likely to be ever-smokers, current daily smokers, and heavier smokers than white-collar workers, and are less likely to quit successfully, although intentions to quit and quit attempts do not differ by occupation. Tobacco use is especially prevalent in certain industries, notably construction and extraction, mining, and hospitality and food services—settings that offer few worksite cessation programs and often lack comprehensive smoke-free policies. The work environment influences patterns of tobacco use prevalence, intensity, and cessation by occupation. Plausible pathways mediating this relationship include work-related stress, work hours, racial discrimination, pro-tobacco social norms, and lack of social support for cessation. Workers’ exposure to job-related hazards appears to be associated with lower interest in quitting and less likelihood of quitting” (NCI 2017b, p. 295).

This section includes studies focused on occupational factors as they relate to disparities in tobacco use and cessation, exposure to secondhand tobacco smoke, and social norms and builds on evidence from NCI Tobacco Control Monograph 22 (NCI 2017b) and the 1985 Surgeon General’s report on workplace influences on tobacco-related health outcomes (USDHHS 1985).

#### Literature Review Methods

To identify the evidence presented in this chapter, the authors searched PubMed, the Social Sciences Citation Index, and Google Scholar for studies that focused on disparities in tobacco initiation, tobacco use, and cessation as they are affected by occupational factors. In particular, the search prioritized meta-analyses and prospective cohort studies, with a focus also on workplace tobacco-free policy implementation. The search, which was not restricted by date, yielded relevant articles published between January 1, 2008, and December 31, 2021, with selected earlier literature included to contextualize the field. Search terms are listed in Appendix 4.1.

The summary and conclusions related to this section were developed by combining the literature cited in previous Surgeon General’s reports with new scientific evidence and by building on conclusions from the section in NCI Tobacco Control Monograph 22 (NCI 2017b) that focused on tobacco-related disparities in the workplace. In addition to adding newer studies, this synthesis includes broader discussions about noncigarette tobacco products, such as e-cigarettes, and also discusses populations, such as people from minoritized sexual orientation and gender identity groups, who were not included in prior reviews.

#### Working Conditions Associated with Tobacco Use

Positive working conditions contribute to improvements in multiple health outcomes (Schnall et al. 2009; Marmot and Bell 2010; Pfeffer 2018), including tobacco use patterns (Sorensen et al. 2004; Albertsen et al. 2006). As documented in NCI Tobacco Control Monograph 22 (NCI 2017b), working conditions may create stressors that contribute to increased tobacco use and barriers to quitting; a health-promoting workplace offers resources that support quitting, including rewards, decision latitude, and social support. Figure 4.3 presents an adapted model, drawing on NCI Tobacco Control Monograph 22 (NCI 2017b) and other sources (Punnett et al. 2009; Sorensen et al. 2016), to illustrate the potential roles of three influences on working conditions: psychosocial exposures, organizational factors, and physical hazards. Stress may serve as one mediator of these work-related exposures.

##### Psychosocial Exposures

Disparities exist in the distribution of social hazards (e.g., violence, discrimination, or harassment that occurs in the workplace) by race and ethnicity, social class, sex, nativity, and sexual orientation and gender identity. According to data from the National Institute for Occupational Safety and Health, after adjusting for other work and demographic factors, being Black, American Indian and Alaska Native, Asian American, or Pacific Islander or being born outside of the United States all remained significant risk factors for being the victim of homicide at work (Steege et al. 2014). Black workers had almost three times the rate of workplace homicide as White workers, and American Indian and Alaska Native, Asian American, and Pacific Islander workers and workers born outside the United States had more than twice the occupational homicide rate of White workers and domestic-born workers, respectively. A study of Indiana nurses found an association between lateral violence in the workplace (i.e., covert or overt acts of aggression between coworkers) and greater risk of tobacco use (Foli et al. 2021).

In addition, researchers have examined the relationship between the experience of social hazards and tobacco use (Steege et al. 2014; Seelig et al. 2017; Chin et al. 2018). A longitudinal analysis of military personnel in the Millennium Cohort Study found that males who used to smoke and who experienced sexual assault had 6.62 times the risk of smoking relapse at follow-up as those who had not experienced such an assault during the time period (Seelig et al. 2017). Similarly, cross-sectional surveys of tobacco use on two military bases (one U.S. Army, the other U.S. Navy) found differential levels of tobacco product use by combat exposure among service members (Chin et al. 2018; Hall et al. 2018b). These studies, which were conducted between 2015 and 2016, found higher levels of tobacco use among service members who were the most likely to be exposed to combat, enlisted men or women (as opposed to officers), and service members who had been deployed a greater number of times.

Job strain has been conceptualized using the demand-control model (Karasek and Theorell 1990), which has shown that jobs characterized by high demand and low control are most detrimental to health. For example, according to cross-sectional surveys of nursing homes in Massachusetts between 2006 and 2007, job strain tends to occur differentially by race or ethnicity (Hurtado et al. 2012). Applying Karasek’s job strain model (Karasek and Theorell 1990) (i.e., a combination of job-related activities of high psychological demand and minimal decision authority to manage demands at work), Hurtado and colleagues (2012) found that risk of job strain was higher among Black workers (relative risk = 2.9; 95% CI, 1.3–6.6) than it was among White workers in the same workplace.

A growing body of literature documents the effects of job strain on smoking, smoking intensity, and quitting (Heikkila et al. 2012; Schantz and Bruk-Lee 2016; NCI 2017a), although some of these findings are inconsistent (Allard et al. 2011; Griep et al. 2015; Rowe et al. 2015a). Some studies have found that job strain is associated with a higher prevalence of smoking (Green and Johnson 1990; Hellerstedt and Jeffery 1997; Lindstrom 2004), and other studies have yielded null findings (Greenlund et al. 1995; Niedhammer et al. 1998; Brisson et al. 2000; van Loon et al. 2000; Ota et al. 2010; Rowe et al. 2015b). A study using latent class modeling suggested that unobserved individual characteristics—such as self-control, stress-coping ability, personality traits, or health preferences—may help to account for these mixed findings and could be included in future studies of this topic (Azagba and Sharaf 2011).

Figure 4.3 Conceptual model of work-related pathways to tobacco use

The work-related pathway to tobacco use includes three potential influences: (1) psychosocial exposures, such as job strain, effort–reward unbalance, social norms, and social support; (2) organizational factors, such as work hours, shifts, and discrimination or harassment; and (3) physical hazards, such as chemical toxins, dust or fumes, noise, and ergonomic strain. Stress is a potential mediator, and potential modifiers include job characteristics, workplace policies, and responses to unfair treatment. These concepts affect the intensity, quitting, and relapse of tobacco use.

Source: Model adapted from NCI Tobacco Control Monograph 22 (NCI 2017b) and other sources (Punnett et al. 2009; Sorensen et al. 2016).

In a systematic review of the effects of the work environment on smoking cessation, relapse, and amount smoked, Albertsen and colleagues (2006) found that high on-the-job demands increased the number of cigarettes smoked among people who smoke and were associated with fewer cessation attempts and an increased probability of relapse.

Work-related social norms and social support may also contribute to disparities in tobacco use. Social support in the workplace may contribute to increased cessation, a decrease in the likelihood of relapse, and a decrease in the number of cigarettes smoked (Griep et al. 2015; NCI 2017a). Other studies have found that smoking may cluster within work groups, potentially indicating the reinforcing role of social norms (Quist et al. 2014), and that quitting may be less likely among those working with other people who smoke (Yong et al. 2014).

##### Organizational Factors

Research on shift work, which is also a psychosocial occupational hazard, indicates that exposure to this stressor may occur differentially across population groups. In studies using nationally representative samples of U.S. workers, workers who were Black or Hispanic and had low levels of education and income were significantly less likely than their counterparts to have control over their work hours, schedules, and breaks and were more likely to work evening and night shifts (Deitch and Huffman 2001; Swanberg et al. 2005). Additionally, working long hours and having either variable shifts or shifts outside the usual workday have been associated with an increased likelihood of smoking (Bannai and Tamakoshi 2014; NCI 2017a). Furthermore, people who work long hours may be less interested in quitting (Yong et al. 2014), and prospective studies have provided evidence that shift work, including working evenings and nights, reduces the likelihood of successful smoking cessation (Eriksen 2005; Sanderson et al. 2005). Finally, working the night shift has been associated with an increased risk of relapse and reduced cessation rates (Nabe-Nielsen et al. 2011; Letri-Mann et al. 2016).

The organizational structure of the workplace may also produce other sources of workplace stress, including bullying, harassment, and discrimination. Exposure to workplace discrimination has been associated with smoking among Black workers (NCI 2017a). A study based on the BRFSS survey’s Reactions to Race module found that workplace discrimination related to race and ethnicity was associated with current smoking in the total sample and with increased current and daily smoking among both Black people and White people (Chavez et al. 2015). Finally, some studies have related smoking status to job insecurity and job loss (NCI 2017a).

##### Physical Hazards

Research indicates that work environments often mirror broader societal imbalances in access to opportunities and resources (Steege et al. 2014). Hazards in the work environment often adhere to the inverse hazard law, which posits an inverse relationship between health hazards and the distribution of power and resources such that people with less power and resources have more hazards in their physical and social environments (Krieger et al. 2011). The inverse hazard law is particularly noteworthy in relation to commercial tobacco use because many of the most harmful chemicals in tobacco smoke—such as carbon monoxide, arsenic, benzene, ammonia, and formaldehyde—are well-documented occupational hazards (Anderson and Wu 2015). Further, diacetyl (2,3-butanedione), a flavoring additive used in some e-cigarette liquids, is the key causal factor in the development of bronchiolitis obliterans (otherwise known as popcorn lung, which is a severe lung disease) among workers in some flavoring and food production industrial settings (Barrington-Trimis et al. 2014; Whitsel et al. 2015; Fechter-Leggett et al. 2018). In addition, the workplace is a source of exposure to other harmful environmental toxicants, such as silica dust, a known cause of multiple diseases including lung cancer (U.S. Department of Labor n.d.).

Tobacco use may increase the risks associated with exposures to occupational hazards (Castellan et al. 2015). This increased risk may be additive (e.g., when workers are exposed to the same toxic chemicals at work and in tobacco products) or synergistic (e.g., when tobacco use increases the risks associated with an industrial hazard, such as asbestos). Tobacco products can become contaminated by workplace chemicals through contact of the products with unwashed hands, contaminated surfaces, or disposition of airborne contaminants. Additionally, the heat that is generated from combusted tobacco products can transform workplace chemicals (e.g., polytetrafluoroethylene, or Teflon, and other chlorinated hydrocarbons) into more toxic chemicals (Castellan et al. 2015). Combusted tobacco products can also pose fire risks for the workplace, especially in occupations involving volatile chemicals. In addition, smoking may contribute indirectly to increased health and safety risks. For example, reduced lung function resulting from smoking may increase workers’ vulnerability to occupational exposures to dust, gases, and fumes and could increase risk of injury (National Institute for Occupational Safety and Health 1979).

Socially disadvantaged workers, including those with lower wages or lower levels of education, are more likely to use tobacco products and to be employed in jobs with exposures to physical hazards (Barbeau et al. 2004; Steege et al. 2014). Additionally, evidence indicates higher levels of exposure to occupational hazards among diverse minoritized racial and ethnic groups, people from sexual orientation and gender identity groups, immigrants and migrants, men (versus women), and people of lower SES (Loomis and Richardson 1998; Murray 2003; Clougherty et al. 2010; Steege et al. 2014).

Finally, exposure to job-related hazards has been associated with reduced interest in quitting smoking (NCI 2017a). Prospective cohort studies, especially studies of smoking cessation interventions, have provided strong evidence that the accumulation of occupational hazards reduces workers’ intentions to engage in tobacco cessation and increases their risk of relapse (Sorensen et al. 1996, 2002; Albertsen et al. 2004). One mechanism that has been posited is that accumulated exposure to occupational hazards leads workers to perceive smoking cessation as futile, especially because occupational hazards and cigarettes often expose workers to the same hazardous chemicals (Sorensen et al. 1996). An alternate mechanism, represented in the CLD model (Figure 4.1), is that smoking serves as a coping response to accumulated exposure to occupational hazards. Such workplace stressors might be associated with lower wage work and financial strain, which may have reinforcing effects on stress and anxiety.

#### Influence of the Work Environment on Disparities in the Initiation and Use of Tobacco Products

Many Americans initiate smoking before their first job, but this is not always the case (Kandel et al. 2011). Compared to non-Hispanic White people, people from other racial and ethnic groups typically initiate smoking at later ages and, as a result, initiation among the members of these groups often coincides with their entry into the labor market (Moon-Howard 2003; Trinidad et al. 2004; Dutra et al. 2017; Cantrell et al. 2018). In addition, research suggests that the age of initiation is increasing overall in the United States (Barrington-Trimis et al. 2020).

##### Cigarettes

Data from studies of military personnel and transit workers indicate that there is a relationship between workplace factors and cigarette smoking initiation and/or subsequent smoking behaviors (Cunradi et al. 2007; Boyko et al. 2015; Brown et al. 2018). For example, in a study of 4,728 military personnel from 24 large U.S. military installations who smoke, increased smoking intensity and nicotine dependence were associated with smoking “to fit in with one’s unit, being in the Army, smoking as a reaction to stress, and work-related stressors” (Brown et al. 2018, p. e231). Additionally, data from a multiethnic cohort of municipal transit operators in San Francisco followed over 10 years (1983–1985 and 1993–1995) found differences in smoking behaviors by race and ethnicity and by workplace factors (Cunradi et al. 2007). Specifically, after adjusting for sex, age, alcohol use, problems at work, work-related burnout, availability of time to unwind from work, and years driving, transit workers who were Black were found to be more likely than those who were Hispanic, Asian or Filipino, White, or classified as Other Race to have smoked over a 10-year period (OR = 1.55; 95% CI, 1.10–2.18; p = 0.01). The only other significant predictor of likelihood of smoking increase, initiation, or maintenance in covariate-adjusted analyses was frequency of job problems, such as accidents, overcrowding, problems with equipment, conflicts with management, crime, communication problems, access to restrooms, or pressure to maintain a schedule (p = 0.004).

The U.S. armed services is a unique federal workplace environment, with a command structure that allows for varied leadership approaches that can differ by branch of service, commander priorities, rank, and deployment status of armed services personnel. These factors combine to foster a complex policy landscape for tobacco prevention and control. The tobacco industry has a long history of targeting military personnel. For example, cigarettes were provided in basic field rations until 1975, when this practice was banned (Smith and Malone 2009). Additionally, cigarettes were sold at deeply discounted prices in commissaries located on military bases prior to the mid-1990s (Smith and Malone 2009). However, since the 1990s, the U.S. Department of Defense has attempted to require that cigarette prices on military bases be similar to those in the surrounding community, to restrict the places where smoking is allowed, and to increase the availability of cessation aids for military personnel who want to quit (Tate 1999; Smith and Malone 2009; USDHHS 2014). Efforts to continue promoting tobaccofree norms among members of the armed services and their families, including efforts to eliminate exposure to secondhand tobacco smoke in multi-unit military housing, deserve future research attention. Furthermore, given the targeted marketing of e-cigarettes and use of emerging tobacco products—such as nicotine pouches—which undermine tobacco-free norms and may impede cessation efforts, efforts are warranted to monitor and counter the availability, appeal, and use of such products by armed services personnel.

##### Smokeless Tobacco

Earlier, an analysis of military personnel using the longitudinal Millennium Cohort Study found an association between workplace environment and initiation of smokeless tobacco use and disparities in such initiation by education and race and ethnicity (Hermes et al. 2012). The authors found a greater likelihood of initiating smokeless tobacco use (between 2001–2003 and 2004–2006) among military personnel who had been deployed to Iraq or Afghanistan than among military personnel who were not deployed to those areas. The study also indicated that a higher risk of initiation was associated with multiple deployments (versus one) to those areas. Service members with less educational attainment, who identified as non-Hispanic White, or who were in the U.S. Air Force, U.S. Navy, or the U.S. Coast Guard were significantly more likely to initiate smokeless tobacco use while in the military than their counterparts who had more education, were from racial and ethnic groups, or were in the U.S. Army. There was no statistically significant difference in the initiation of smokeless tobacco between service members in the U.S. Marine Corps compared with those in the U.S. Army (Hermes et al. 2012). However, Lin and colleagues (2018) found that the prevalence of smokeless tobacco use was higher among service members in the U.S. Army (stationed at Fort Liberty, then Fort Bragg, Army Base in North Carolina) (32.6%) than it was among those in the U.S. Air Force (stationed at Lackland Air Force Base in Texas, which is part of Joint Base San Antonio) (11.6%). Compared with U.S. Air Force service members, U.S. Army service members who used smokeless tobacco products were heavier users with longer durations of use, were more likely to have started using smokeless tobacco after joining the military, and were less likely to make a quit attempt.

Firefighters are another population at risk for occupational disparities in the use of specific tobacco product types. Jitnarin and colleagues (2017) examined late initiation of smokeless tobacco use—that is, beginning use as an adult after joining the fire service—among male firefighters in the United States. They used age-standardized data on males from the U.S. Census and age distributions from the 2011 U.S. Department of Defense Health-Related Behaviors Survey (HRBS) of Active Duty Military Personnel as comparison groups to compute estimates of smokeless tobacco use among U.S. adult males in the general population and male military personnel. The study found a possible relationship between the fire service and the initiation of smokeless tobacco use. After age-standardizing results to men in the military who also have high rates of smokeless tobacco use, the study found that a statistically significant proportion of male firefighters, who never used smokeless tobacco before joining the fire service, initiated use after joining the fire service. Firefighters also initiated smokeless tobacco use at a later age than their counterparts in the military and general population. Although this analysis did not examine differences in the initiation of smokeless tobacco use by demographic characteristics, more than 80% of the sample of firefighters were White and male. The use of e-cigarettes or other noncigarette tobacco products was not assessed.

##### E-Cigarettes

Data from the 2014 NHIS showed differences in the use of e-cigarettes by occupation (Syamlal et al. 2016), with workers in the accommodation and food services industry and with occupations in food preparation and as food servers having the highest prevalence of e-cigarette use compared with people working in education services and in occupations in architecture, engineering, and computer and mathematical fields (who had the lowest prevalence of e-cigarette use) (also see Chapter 2 of the current report). In addition, several studies have found that many people who use e-cigarettes report using e-cigarettes in situations in which they cannot smoke cigarettes indoors, including in the workplace (Czoli et al. 2014; Li et al. 2014; Tucker et al. 2014; Ambrose et al. 2015; Kong et al. 2015; McDonald and Ling 2015; Suris et al. 2015). None of these studies, however, considered differences in the influence of workplace factors on e-cigarette use across demographic or racial and ethnic groups. Notably, much of the existing research on this topic was conducted before the proliferation of local laws mandating smokefree indoor air included e-cigarettes (Marynak et al. 2017). Additionally, these prior studies on the effects of the work environment on patterns in e-cigarette use may be less replicable given the rapidly changing landscape of noncigarette tobacco products, shifting patterns in use over time, and social norms about different types of tobacco products.

##### Multiple Product Use

In the 2008 HRBS among active duty military personnel, cigarette, smokeless tobacco, and cigar use was highest among young male (17–20 years of age and 20–25 years of age) U.S. Marine Corps and U.S. Army personnel, non-Hispanic White personnel, personnel with less than a college education, and personnel in lower pay grades (Olmsted et al. 2011). In adjusted analyses, compared with military personnel who identified as “Other race,” non-Hispanic White service members were at higher risk of using cigarettes, smokeless tobacco, and cigars; cigarettes and smokeless tobacco in combination; and all three products together, and non-Hispanic Black and Hispanic service members were at lower risk of cigarette and smokeless tobacco use. This study also found an inverse relationship in the risk of using cigarettes, cigarettes and smokeless tobacco together, and all three products (cigarettes, smokeless tobacco, and cigars) together by level of educational attainment and pay grade. Risk of e-cigarette use was not assessed because they were not widely available when these data were collected in 2008.

However, additional studies have used more recent administrations of the HRBS to assess the dual use of e-cigarettes and other tobacco products. Keltner and colleagues (2021), using data from the 2015 HRBS in adjusted analyses, found that service members who were of rank enlisted (compared to rank of Officer), who lacked a bachelor’s degree (compared to having a bachelor’s degree or higher educational attainment), and who had a probable alcohol use disorder (compared to not having one) had significantly greater odds of dual use of e-cigarettes and cigarettes. Additionally, Smucker and colleagues (2021), using data from the 2018 HRBS, found that active service members who used both e-cigarettes and other tobacco products (including cigarettes, chewing tobacco or snuff, cigarillos or cigars, or pipes and hookahs) during the past 30 days were more likely than active service members who did not use tobacco products to report a physiciandiagnosed medical condition and to have lower selfreported physical health, serious psychological distress, and insufficient sleep. Furthermore, service members who used both e-cigarettes and other tobacco products reported worse health outcomes than service members who had exclusively used e-cigarettes or exclusively used other tobacco products.

#### Influence of Work Environments on Disparities in Tobacco Cessation and Relapse

Notably, multiple studies have found an association between workplace factors and disparities in tobacco cessation and relapse by sex, age, race and ethnicity, rurality/urbanicity, and SES (Brissette et al. 2008; Steege et al. 2014; Tsai et al. 2018; Buettner-Schmidt et al. 2019; Park et al. 2019; Syamlal et al. 2019).

##### Coverage of Tobacco Cessation Treatment, Tobacco Surcharges, and Considerations

Having health insurance coverage for evidencebased tobacco cessation treatment increases the likelihood of successful long-term tobacco cessation (Kaper et al. 2005; Reda et al. 2009; van den Brand et al. 2017). Most of the U.S. population obtains health insurance through their workplaces (Boal et al. 2018; Berchick et al. 2019), but based on 2020 U.S. Census data from the Current Population Survey’s Annual Social and Economic Supplement, 13.0% of full-time, year-round workers do not have private health insurance (Keisler-Starkey and Bunch 2021). In 2014, the estimated prevalence of being an uninsured worker in the United States was greatest for Hispanic people (33.3%), followed by non-Hispanic Black people (15.5%) and non-Hispanic White people (8.6%) (Boal et al. 2018).

The Patient Protection and Affordable Care Act of 2010 requires most private health insurance plans to cover tobacco screening and cessation treatments, but it also allows certain health plans to implement surcharges for people who use tobacco (i.e., employers can require workers who smoke to pay higher insurance premiums than workers who do not smoke) (Friedman et al. 2016). The higher cost of health insurance for people who smoke may encourage some people to quit smoking, but the higher cost may also worsen financial insecurity and widen tobacco-related health disparities among people who have difficulty quitting. An analysis of 2011–2014 data from the BRFSS found that tobacco surcharges did not improve smoking cessation (Friedman et al. 2016). In 2016, a survey of a random sample of 300 public or private small employers in the United States revealed that only 16.2% of employers used tobacco surcharges to provide tobacco cessation resources for their employees (Pesko et al. 2018). The use of these surcharges for cessation resources occurred differentially based on the salary environment: 19.0% of higher paying employers used surcharges to provide these resources, and only 7.4% of lower paying employers did so.

Insurance coverage for smoking cessation differs by workplace characteristics (Kaper et al. 2005; Reda et al. 2009; van den Brand et al. 2017), and work-places offer different cessation resources to employees. For example, Hughes and colleagues (2011) conducted a cross-sectional analysis of the 2008 Health Worksite Survey, which collected corporate health policy data from Washington state employers with 50 or more employees, finding that restaurants, bars, and lounges where less than 75% of workers had health insurance were less likely than other workplaces to offer cessation resources, such as referrals to state quitlines, to their employees. The demographic composition of the workplaces was not reported, but restaurants, bars, and lounges in the United States disproportionately employ people of lower SES as well as Black and Hispanic people (U.S. Bureau of Labor Statistics 2017, 2019).

The workplace environment is a setting that can encourage tobacco-free social norms, for example, by providing smoking cessation resources to employees and maintaining a smokefree environment. However, according to the 2014–2015 TUS-CPS, only 27.2% of working adults had a workplace that offered smoking cessation programs (Syamlal et al. 2019). Among indoor workers in that study, those who were White, had higher levels of income and educational attainment, worked in the Midwest, or were employed in workplaces with comprehensive smokefree policies had the highest access to workplace smoking cessation programs. The analysis from Syamlal and colleagues (2019) also showed that 80.3% of people who worked indoors reported 100% smoke-free policies at work (estimated to protect 84.0 million workers) and 27.2% of people who worked indoors and outdoors reported access to employer-sponsored cessation programs.

##### Exposure to Secondhand Tobacco Smoke in the Workplace

The 2006 Surgeon General’s report, The Health Consequences of Involuntary Exposure to Tobacco Smoke, identified the workplace as a major source of secondhand tobacco smoke for adults (USDHHS 2006). Secondhand tobacco smoke has been causally linked to cardiac disease and lung cancer for people who do not smoke (Barnoya and Glantz 2005; USDHHS 2006; Kim et al. 2018). Notably, workplace smokefree policies have resulted in less smoking among workers covered by these policies (USDHHS 2006).

Differences exist in workplace exposure to secondhand tobacco smoke by sex, occupation, race and ethnicity, SES, and rurality (Gonzalez et al. 2013; Tsai et al. 2018; Buettner-Schmidt et al. 2019; Park et al. 2019). TUS-CPS data from 2003 and 2010–2011 indicated that female workers were more likely than male workers to work in a smokefree workplace in all occupational categories except for service (Babb et al. 2018).

A literature review by Angus and Semple (2019) found high levels of exposure to secondhand tobacco smoke among women in certain professions. The authors reviewed 17 studies (11 using U.S. samples) that primarily involved either cross-sectional questionnaires or qualitative studies (such as focus groups) and were published between 1993 and 2017. The authors concluded that home health workers, of whom 90% were female (Angus and Semple 2019), experienced high levels of exposure to secondhand tobacco smoke. The studies included in the literature review indicated that between 31% and 83% of home health workers had been exposed to secondhand tobacco smoke on the job (based on self-reports) (Stephany 1993; Markkanen et al. 2007; Keske et al. 2013).

Several studies have found differential exposure to secondhand tobacco smoke by worker characteristics other than sex (Harris et al. 2011; King et al. 2014). Per the 2009–2010 NATS, for example, 20.4% of non-smoking employed adults had been exposed (per self-reports) to secondhand tobacco smoke in the workplace during the previous 7 days (King et al. 2014). The prevalence of exposure was higher among males compared with females; among Black, Hispanic, and American Indian and Alaska Native people compared with White people; and among those with less education and income compared to those with more education and higher income. Exposure did not differ significantly by LGBT status.

In their study of indoor workers (n = 23,820) in Missouri, Harris and colleagues (2011) found intersections in risk across disparity group status and exposure to secondhand tobacco smoke in rural workplace environments. Although the overall rate of workplace exposure to secondhand tobacco smoke statewide was estimated to be 11.5%, models showed that in lower SES rural areas across Missouri, at least 40% of non-smoking young adult White males and 50% of non-smoking young adult Black males were exposed to secondhand tobacco smoke in the workplace, suggesting disparities among workers, by geography and race, in exposure to secondhand tobacco smoke.

##### Workplace Social Norms and Social Support

The connection between smokefree environments, including smokefree worksites, and a reduction in tobacco use is well established (Rose et al. 2011; NCI and WHO 2016; Cheng et al. 2017). The impact of smokefree work environments extends well beyond worksites and workers. For example, research supports the existence of “norm spreading,” in which policies prohibiting smoking in public places stimulate people to subsequently enact voluntary smoking restrictions in private spaces, such as in their homes and vehicles (Cheng et al. 2011, 2015).

Few studies have examined the relationship between having work breaks—one aspect of workplace social norms—and patterns of smoking cessation and relapse. In a qualitative study composed of 71 transit workers in California, 83% of whom were African American people who currently smoked or used to smoke, work breaks were reported as a key trigger for smoking relapse (Battle et al. 2015). In contrast, in a quantitative survey of 935 California transit workers of whom 60% were African American, perceived ease of taking a smoking break during a shift was not associated with smoking status, a finding that was contrary to the authors’ hypothesis (Cunradi et al. 2017). One might logically assume that people who smoke have elevated attention to break times during the workday to smoke because of nicotine dependence compared to people who do not smoke; however, the relationship between taking breaks in the workplace and tobacco use merits further research, given that the available evidence on this relationship is unclear.

Both systematic reviews and the results of studies on cessation interventions have found a positive correlation between support for a non-smoking work environment and successful smoking cessation (Albertsen et al. 2006; Sorensen et al. 2009). A supportive and trusting environment also appears to be associated with lower tobacco use. For instance, a prospective study of certified nursing assistants (CNAs), which is an occupational group that tends to receive much lower wages compared with other types of nurses, 90% of whom were female and 12.5% of whom were African American, assessed the impact of an intervention designed to create a supportive supervisory and organizational climate, but the intervention did not have a tobacco control component. The intervention reduced workers’ weekly cigarette consumption on average by about seven cigarettes, with even stronger reductions in cigarette consumption found for U.S.-born, non-Hispanic White CNAs compared to CNAs from other racial and ethnic groups (Hurtado et al. 2016). It is important to note that this analytic sample lacked racial or ethnic diversity and that non-White people were combined in the analysis. Findings speak to the potential for a supportive work environment to promote less smoking among nurses with lower wages.

In contrast, a randomized controlled trial of a workplace wellness program conducted at small, lower wage worksites between 2014 and 2017 found that workplace cessation programs were not associated with smoking status, use of smokeless tobacco, or quit attempts (Kava et al. 2019). Even so, the presence of worksite cessation programs was associated with workers reporting that their workplace was invested in their cessation efforts.

Consistent with the conclusions of the 1985 Surgeon General’s report, the existing literature indicates that, after statistical controls for age, sex, educational attainment, and race and ethnicity, occupational factors remain significant predictors of tobacco use behaviors, including age of initiation, quit attempts, engagement in cessation, and success in cessation attempts (Haenszel et al. 1956; Sterling and Weinkam 1976; Nelson et al. 1994; Leigh 1996; Giovino et al. 2000; Lee et al. 2007; Sorensen and Barbeau 2012).

#### Work Environment Summary

Cross-sectional and prospective cohort studies have provided consistently strong evidence that work-related stress and occupational hazards are associated with tobacco product use and initiation and inversely associated with smoking cessation. The existing literature focuses primarily on cigarette smoking and cessation, and research about the initiation of other tobacco products is limited. Despite evidence that the association between work-related stressors and smoking initiation varies by race and ethnicity, many of the studies in this review that examined the impact of workplace stressors and occupational exposures did not assess differences by race and ethnicity. Thus, one limitation of the studies in this review is that the contribution of the work environment to existing disparities in smoking initiation remains underexplored among people from certain racial and ethnic, SES, and sexual orientation and gender identity groups.

Within the existing research on occupational factors and tobacco, several studies have established a relationship between specific aspects of the work environment and tobacco use or cessation. Smokefree workplaces remain unevenly distributed across occupational groups, despite strong evidence of their effectiveness to reduce exposure to secondhand tobacco smoke, the consumption of cigarettes, and the prevalence of smoking. In fact, there are disparities by gender, type of occupation, race and ethnicity, SES, and rurality in exposure to secondhand tobacco smoke in the workplace. There may be interacting effects of multiple demographic characteristics with types of occupations on exposure to secondhand tobacco smoke. However, additional research is needed to understand these complex interactions, especially given the tobacco product-related disparities among people with intersectional identities. Further, the association between workplace social norms related to tobacco product use and smoking cessation may vary by race and ethnicity. Future research utilizing multilevel studies will be critical to understanding these relationships because the uneven distribution of state and local smokefree policies can contribute to diverging social norms related to tobacco products in the workplace.

Despite evidence of disparities—by race and ethnicity, sexual orientation and gender identity, immigration status, gender, and SES—in exposure to physical and social occupational hazards, research is limited on how the associations between these hazards in the workplace and tobacco product use and smoking cessation vary by these demographic characteristics. Additional stratified analyses are needed that can provide more information about these potential disparities. Future research could also consider latent class modeling because it can elucidate unobserved factors that are related to the workplace environment and tobacco use. The utilization of mediation analyses might also help to further understand the mechanisms that explain these relationships between work-related stressors and occupational hazards and tobacco product initiation, use, and cessation.

Studies on additional job characteristics that may impact disparities in smoking behaviors are also warranted. For example, employers are increasingly relying on nonstandard, less secure work arrangements (e.g., day laborers for temporary construction work), and Hispanic people and immigrants are disproportionately represented in these nonstandard work arrangements (Flynn et al. 2015). In addition, studies are needed to investigate tobacco product-related disparities using more recent data that reflect the evolving nature of employment (e.g., gig economy workers, such as ride app drivers or food delivery workers) and work environments in the United States (e.g., remote/teleworkers) and the emergence of e-cigarettes and other noncigarette tobacco products.

### Healthcare Environment

Although the prevalence of smoking in the United States has declined steadily over the past several decades, the decline has not been distributed equally across SES levels or racial and ethnic groups (Cornelius et al. 2020). Such disparities are partially attributable to differential access to evidence-based tobacco cessation resources in the healthcare environment. The 2020 Surgeon General’s report on smoking cessation reviewed the evidence on clinical tobacco cessation interventions, stating that “the prevalence of key indicators of smoking cessation—quit attempts, receiving advice to quit from a health professional, and using cessation therapies—also varies across the population, with lower prevalence among some subgroups” (USDHHS 2020, p. 6). This section takes a more in-depth view of the role of the healthcare environment in tobacco-related health disparities. Because people with limited economic resources often have less access to cessation resources, it is especially critical to improve the reach and impact of these resources for underserved populations (Browning et al. 2008; Cokkinides et al. 2008; Shiffman et al. 2008; Husten 2010; Trinidad et al. 2011; Jamal et al. 2012). This section details how differential access to care in the healthcare environment—including not having access to cessation resources and services, facing specific challenges to accessing cessation resources in mental healthcare and substance use treatment facilities, and lacking access to health insurance coverage of cessation treatments—may influence tobacco-related health disparities.

#### Literature Review Methods

This review is based on a thorough literature search conducted using the PubMed and PsycINFO databases. These databases were utilized because they include virtually all indexed journals that publish peer-reviewed research on tobacco assessment and intervention in the healthcare environment. Specific search terms are listed in Table A4.1. For inclusion in the review, studies had to meet all the following criteria: peer-reviewed, conducted in the United States, examined racial and ethnic and socioeconomic disparities in the assessment of tobacco use or delivery of tobacco treatment in healthcare and substance use and mental health treatment settings, and published between January 1, 2008, and December 31, 2021.

#### Disparities in Clinical Cessation Interventions

Findings from the 2000, 2005, 2010, and 2015 NHIS showed nationwide improvements in cessation-related indicators, including overall increases in the proportion of adults who smoke and who reported key milestones in the quitting process, such as (1) making a recent quit attempt, (2) having received advice to quit from a health professional, (3) using evidence-based treatment (behavioral counseling and/or cessation medication), and (4) achieving smoking cessation (Babb et al. 2017). Although each of these milestones is important, delivering cessation advice and promoting the use of evidence-based treatment are highlighted here because they reflect the direct involvement of the healthcare system.

Receiving cessation advice from a healthcare provider is effective for all people who smoke, including those who identify with minoritized racial and ethnic populations (Sanderson Cox et al. 2011), but disparities persist in having received such advice. A 2015 study showed that 57.2% of adults who currently or formerly smoked and who had seen a health professional in the preceding year reported having received advice to quit from a healthcare professional, the highest prevalence since 2005 (Babb et al. 2017). However, a lower percentage of non-Hispanic Asian adults (34.2%), American Indian and Alaska Native adults (38.1%), and Hispanic adults (42.4%) reported having received advice to quit from their providers compared with non-Hispanic White adults (60.2%); 55.7% of non-Hispanic Black adults reported having received advice to quit, but 95% confidence intervals overlapped with that of non-Hispanic White adults. Similarly, a lower percentage of people without health insurance (44.1%) reported having received advice to quit compared with those with any insurance (range: 56.8–69.2%) (Babb et al. 2017). Similar findings have been reported using 2018–2019 TUS-CPS data, with a lower percentage of Hispanic adults than White adults reporting having received advice to quit from a physician (NCI 2022a, b).

In a retrospective study of recent quitters responding to the TUS-CPS, receiving advice to quit smoking from a healthcare provider increased modestly over time, from 66% (standard error [SE] = 2%) in 2007 to 73% (SE = 4%) in 2015, mirroring the positive trend observed in other national surveys (Mai and Soulakova 2018). In the same study, the adjusted odds of having received advice to quit smoking from a healthcare provider were lower among Hispanic adults compared with non-Hispanic White adults (aOR = 0.66; 95% CI, 0.47–0.92) (Mai and Soulakova 2018). This trend of increased prevalence of having received advice to quit from a healthcare professional was also reflected in a study comparing 2010 to 2015 NHIS data, where Tan and colleagues (2018) noted the persistence of disparities in having received such advice, particularly among people with lower income, people who were uninsured, and members of specific racial and ethnic groups.

Additional studies have showed lower rates of having received advice to quit smoking from healthcare providers, along with other aspects of tobacco cessation treatment, for non-Hispanic Black and Hispanic people who smoke (Cokkinides et al. 2008; Bailey et al. 2018; Babb et al. 2020), although this varies by Hispanic population group (Babb et al. 2020). It is notable, however, that the disparity between non-Hispanic White and Hispanic adults who smoke in having received advice to quit from a healthcare provider has narrowed over time, from a peak difference of 13.3 percentage points (72.3% vs. 59.0%) in 2010–2012 to 7.0 percentage points (76.4% vs. 69.4%) in 2013–2015 (SEs <5.3%) (Mai and Soulakova 2018). This decrease potentially reflects the reduction in the uninsured proportion of Hispanic people over this period as a result of the Patient Protection and Affordable Care Act (Sommers et al. 2015).

The reasons underlying the observed disparities in having received advice to quit smoking from a healthcare provider remain unclear. A preliminary study by Landrine and colleagues (2018) examined predictors of receiving such advice. Consistent with other published findings, the odds of having received advice to quit from a healthcare provider were 2.39 times (95% CI, 1.38–4.14) higher among White people who smoked than they were among Black people who smoked. Among White people, no predictors of receiving advice emerged, but among Black people, both men and young people were less likely to have received advice (Landrine et al. 2018). Other studies have suggested that disparities in having received advice to quit smoking may be related, in part, to decreased access to healthcare among priority populations. Babb and colleagues (2020) found a higher proportion of Hispanic adults (vs. non-Hispanic White adults) who smoked had not visited a provider in the preceding year (27.7% vs. 14.7%). In another study of Medicaid-enrolled people in California who smoked, ethnic-related disparities in having received advice to quit were not significant when taking into account the number of clinical visits; those with greater numbers of clinical encounters were more likely to have received advice to quit (aOR = 1.99; 95% CI, 1.15–3.43) (Valencia et al. 2022). In a study of Asian American people in California who smoked, only half (50.8%) reported visiting a provider in the preceding year; factors associated with having received advice to quit included health insurance status and smoking intensity (Tong et al. 2011).

Evidence-based smoking cessation treatment, including behavioral counseling and pharmacotherapy, improves the likelihood of quit success (USDHHS 2020). However, utilization of these treatments is generally low, and disparities in utilization exist (USDHHS 2020). In a study of 2015 NHIS data, Babb and colleagues (2017) reported variations in the utilization of evidence-based treatment (counseling and/or medication): Hispanic and non-Hispanic Asian adults reported lower treatment use than non-Hispanic White adults (19.2% and 20.5% vs. 34.3%, respectively); adults without health insurance reported lower treatment use than privately insured adults (21.4% vs. 32.1%); and adults identifying as gay, lesbian, or bisexual reported lower treatment use than adults identifying as straight (14.5% vs. 31.7%). Other studies have had similar findings. For example, in an analysis of 2003 TUS-CPS data, Trinidad and colleagues (2011) found that, among people who smoked, people who identified as African American, Hispanic, Asian American, or Pacific Islander were less likely than White people to have used nicotine replacement therapy (NRT) during their last quit attempt. A study of U.S. Department of Veterans Affairs medical and ambulatory care centers, where access to services is available to all patients, found that only 36% of African American and 26% of Hispanic patients who smoked used NRT during a quit attempt compared with 50% of White patients who smoked, despite the fact that African American and Hispanic patients were more likely than White patients to make a quit attempt (Fu et al. 2005). In a more recent analysis of 2014–2016 data from 143 safety-net primary care clinics in 12 states, Bailey and colleagues (2018) found that patients who were uninsured and non-White were significantly less likely to have received both counseling and medication than were people who were insured and White.

Taken together, these findings suggest an urgent need, in particular for people from minoritized racial and ethnic groups and lower SES groups, to design health systems that (a) systematically screen all people for tobacco use and (b) effectively provide them with, or refer them to, evidence-based tobacco cessation treatment services (Husten 2010; USDHHS 2020).

#### Tobacco Cessation Resources in Mental Health and Substance Use Treatment Facilities

Although progress has been made in decreasing the prevalence of cigarette smoking among people with mental health conditions and/or substance use disorders, substantial disparities in tobacco use remain for this group (Prochaska et al. 2017; Han et al. 2022). Although motivation to quit smoking is generally high within these specific populations (Siru et al. 2009), intensive treatments may be required to successfully facilitate cessation (CDC 2013). Mental health and substance use treatment facilities are well-positioned to deliver high-quality, intensive tobacco cessation treatment to people with high levels of need. One key barrier to integrating treatment for tobacco cessation in these settings is the longstanding misconception among mental healthcare providers that smoking mitigates symptoms associated with mental illness or adaptively modifies neurobiological pathways for mental health patients, a belief perpetuated by industry-funded research that has contributed to a culture of acceptance of tobacco use on the grounds of mental health treatment facilities (Hall and Prochaska 2009; Schroeder and Morris 2010). In an effort to overcome this and other barriers, multiple national initiatives have been launched to facilitate the integration of treatment for tobacco use as part of mental health services (Christiansen et al. 2016). For example, in Treating Tobacco Use and Dependence: Clinical Practice Guideline, also known as the Clinical Practice Guideline, the U.S. Public Health Service called for the implementation of systems changes to facilitate the delivery of treatment services for tobacco cessation in mental health treatment facilities (Fiore et al. 2000). Similarly, the Substance Abuse and Mental Health Services Administration has supported both grants and state-level leadership academies to facilitate the integration of tobacco treatment in these facilities (Santhosh et al. 2014).

Integration of tobacco cessation services in treatment settings for mental health conditions and substance use disorders has not been optimal (Hunt et al. 2013). For example, Marynak and colleagues (2018) found that in 2016, fewer than half of these facilities offered evidencebased tobacco cessation treatment to their clients. An important caveat here, however, is that the provision of tobacco treatment in these facilities varies substantially across states. For example, in 2016, the provision of tobacco treatment in mental health treatment facilities ranged from a low of 20.5% in Idaho to a high of 68.8% in Oklahoma, and the provision of tobacco treatment in substance use treatment facilities ranged from a low of 26.9% in Kentucky to a high of 85.0% in New York (Marynak et al. 2018). Of note, Abraham and colleagues (2017) found that tobacco cessation services in facilities treating substance use were significantly more likely to be provided in states with higher cigarette excise taxes and higher levels of spending on tobacco prevention and control.

#### Access to Insurance and Resources for Tobacco Cessation

Tobacco-related health disparities are partially driven by the inability of lower income people to pay for the cost of tobacco cessation treatment. The prevalence of smoking in 2018 among adults enrolled in Medicaid is more than twice that of privately insured adults (23.9% vs. 10.5%, respectively) (Creamer et al. 2019). Accordingly, providing insurance coverage for cessation treatment is critical for improving access to care (Chen et al. 2016). The Patient Protection and Affordable Care Act requires coverage of all U.S. Preventive Services Task Force A and B graded services, including tobacco cessation treatment, for most private health insurance plans as well as for state Medicaid expansion plans. However, only 19 states had comprehensive coverage of cessation treatment for all enrollees in traditional Medicaid plans as of June 20, 2022 (CDC 2022), coverage barriers (e.g., copays, prior authorizations) remain (McMenamin et al. 2018; DiGiulio et al. 2020), and utilization of cessation treatment is low (Babb et al. 2017). Effectively engaging adults who smoke in evidence-based treatment is a critically important priority for public health policy (Ku et al. 2016).

The 2020 Surgeon General’s report on smoking cessation concluded that, “with adequate promotion, comprehensive, barrier-free, evidence-based cessation insurance coverage increases the availability and utilization of treatment services for smoking cessation” (USDHHS 2020, p. 11). However, having health insurance is not sufficient in and of itself to support and increase tobacco cessation. For example, Brown and colleagues (2016), who examined associations between tobacco use and having health insurance in a large, nationally representative sample of women of reproductive age, found that pregnancy status significantly moderated the relationship between health insurance status and tobacco use. Specifically, among pregnant women, having health insurance was not associated with past-month tobacco use; in contrast, among nonpregnant women, having health insurance was significantly associated with a lower likelihood of using tobacco. The authors concluded that tobacco use persists during pregnancy despite the presence of insurance, suggesting that prenatal visits may miss opportunities to deliver cessation interventions.

Increasing access to cessation treatment among vulnerable and underserved populations will require commitments from both private and public health insurance companies and publicly funded healthcare programs. Specifically, insurers will need to (a) provide comprehensive coverage for evidence-based treatments and inform enrollees that such coverage and benefits are available; (b) remove barriers to accessing treatment, including deductibles, copays, and the need for prior authorizations; and (c) ensure that all enrollees who use tobacco have access to affordable, accessible, and evidence-based tobacco treatment to reduce tobacco-related health disparities. For instance, partnerships between healthcare organizations and quitlines, which are available in all 50 states, have been examined as an intervention strategy that can decrease barriers to accessing evidence-based smoking cessation services through the healthcare system (Vidrine et al. 2010). These partnerships are discussed further in Chapter 7.

#### Healthcare Environment Summary

Evidence reviewed in this section regarding disparities in access to, and utilization of, clinical cessation interventions reveals a persistent pattern of disparities, particularly among minoritized racial and ethnic groups and lower SES groups. Although the overall prevalence of having received advice to quit smoking from a healthcare provider has increased over time, disparities persist. Disparities—including those by race and ethnicity, SES, sexual orientation, and health insurance status—also exist in the utilization of evidence-based cessation treatments.

Substantial disparities exist in the provision of tobacco cessation treatments in mental health and substance use treatment settings. In 2016, fewer than half of all such facilities in the United States offered evidencebased tobacco cessation treatments to their clients, with wide variation across states. Finally, a lack of adequate insurance coverage for evidence-based tobacco treatments has resulted in poorer treatment access among people with fewer economic resources. Taken together, these factors are important contributors to tobacco-related health disparities. Effectively mitigating these disparities will require barriers to be addressed at the patient, provider, and system levels.

## Summary of the Evidence

The concluding remarks in this section highlight the strongest and most consistent relationships between social and environmental influences and tobacco-related health disparities. Studies reviewed in this chapter demonstrate that social influences from family members and peers are associated with tobacco product use among adolescents. Such characteristics as parental connectedness and peer smoking may also play a role in initiation and in transitioning to regular use of tobacco products. Further, the impact of these family and peer influences on smoking varies by race and ethnicity and gender. Specifically, studies show that peer smoking is associated with smoking among White, Black or African American, and Hispanic or Latino adolescents; further, greater exposure to peer smoking or smoking in the home among White youth might account for some of the racial and ethnic gaps observed in cigarette smoking rates among White youth compared to Black or African American and Hispanic or Latino youth. Exposure to parental smoking is also associated with adolescent smoking, and the relationship is similar across racial and ethnic groups.

Studies have found a strong and consistent positive association between discrimination and tobacco product use among Black and African American people but inconsistent effects among Hispanic or Latino and White people. Results from one study also suggest an association between structural stigma related to same-sex marriage and smoking among LGBT people. Further, important racial and ethnic and gender disparities are present in the role of acculturation in tobacco product use and cessation. Studies demonstrate that among Hispanic or Latino and Asian immigrants, interacting effects are evident between acculturation and gender on smoking. Among these two racial and ethnic groups, tobacco product use is higher among women who are acculturated compared to women living in their respective heritage countries. However, tobacco use is generally lower among men who are acculturated compared to men living in their respective heritage country.

The home environment also impacts tobacco-related outcomes within and across populations. Studies demonstrated significant disparities in exposure to secondhand tobacco smoke in the home by race and ethnicity, SES, home ownership, the presence of smokefree policies in multi-unit housing, and voluntary smokefree rules in a home. Unequal protections by smokefree policies among people living in multi-unit housing can contribute to disparities in exposure to secondhand tobacco smoke. Secondhand tobacco smoke can enter the homes of people who do not smoke and who live in multi-unit housing complexes that lack smokefree policies, including in public or government-subsidized multi-unit housing provided for lower income populations. Furthermore, existing evidence shows that Black or African American and Hispanic or Latino residents are more likely than White residents to be exposed to secondhand tobacco smoke in multi-unit homes even if they do not smoke or have smokefree rules that do not allow smoking in the home.

Most adolescents spend a majority of their time in schools, and certain aspects of the school environment can impact tobacco product use and initiation. The evidence demonstrates that Black or African American and Hispanic or Latino adolescents who are connected to school—either through relationships with educators or through participation in extracurricular activities—or who have an increased sense of belonging at school are less likely to initiate cigarette smoking than their counterparts who do not feel connected to school or who experience discrimination at school. Unfortunately, multiple studies suggest that Hispanic or Latino and Black or African American students generally feel less connected to the school environment than White and Asian American youth and are more likely to report discrimination at school, which is associated with a higher likelihood of cigarette smoking. These differences in school bonding (i.e., school attachment, belongingness, and connectedness) and school climate and interactions can contribute to tobacco productrelated disparities among the most disproportionately impacted adolescent populations. Further, having health centers and tobacco prevention policies and programs in schools appears to be associated with a lower prevalence of tobacco product use. However, studies have suggested that inequitable access to school health centers and the inequitable implementation of tobacco-free policies and tobacco prevention programs in schools may leave certain racial and ethnic and socioeconomic groups of adolescents unprotected.

The work environment can also impact tobacco product initiation, use, and cessation. Evidence from the studies reviewed shows that work-related stressors and occupational hazards are associated with smoking initiation, reduced motivation among workers to participate in smoking cessation programs, less success with cessation, and increased risk of relapse after successful cessation. Racial and ethnic disparities also exist in the associations between work-related stressors and occupational hazards and tobacco product-related outcomes. Additionally, due to variations in workplace social norms and the uneven distribution of state and local smokefree policies, disparities in exposure to secondhand tobacco smoke in the workplace exist by gender, occupation, race and ethnicity, SES, and geography. The impact of increases in remote working following the COVID-19 pandemic on tobacco product initiation, use, cessation, relapse, and related disparities is an important area for future research.

Although the prevalence of having received advice to quit smoking from a healthcare provider has increased over time for the overall population, evidence shows that disparities persist, particularly among minoritized racial and ethnic groups and lower SES groups, in having received such advice. Additionally, disparities are apparent in the utilization of evidence-based cessation treatments (i.e., counseling, pharmacotherapy), particularly among groups defined by race and ethnicity, SES, and health insurance status. Mental health and substance use treatment settings continue to broadly underutilize tobacco cessation treatment, despite the disproportionately high rate of smoking among people with mental health conditions and substance use disorders. Each clinical encounter is an opportunity to provide treatment and referral to more comprehensive cessation services for people who use tobacco. Delivery of evidence-based tobacco cessation treatment and barrier-free insurance coverage of these treatments should be a high priority for healthcare systems and insurance plans, with an emphasis on optimal application in mental healthcare settings.

## Conclusions

1. Tobacco use among peer groups increases the likelihood of smoking initiation for White, Black, and Hispanic adolescents.
2. For adolescents, participating in extracurricular activities or feeling a sense of belonging at school can reduce the likelihood of cigarette smoking initiation. However, Black and Hispanic adolescents report lower school connectedness than White adolescents, which may increase the likelihood of smoking initiation.
3. As Asian American and Hispanic or Latino immigrants undergo acculturation to life in the United States, there is a greater risk of cigarette smoking among women and a reduced risk of smoking among men.
4. Inequitable smokefree protections for people living in multi-unit housing contribute to disparities in exposure to secondhand tobacco smoke.
5. Although smokefree policies in the workplace can reduce the use of tobacco products and encourage quitting, not everyone is evenly protected by these policies. Work-related stress and exposure to occupational hazards are linked to smoking initiation and difficulty quitting smoking.
6. Disparities in utilization of evidence-based cessation treatments exist, including by race and ethnicity, socioeconomic status, and health insurance status. Disparities persist in having received advice to quit smoking from a healthcare professional, particularly among minoritized racial and ethnic groups and lower socioeconomic status groups.

## References

Abraham AJ, Bagwell-Adams G, Jayawardhana J. Availability of tobacco cessation services in substance use disorder treatment programs: Impact of state tobacco control policy. Addictive Behaviors 2017;71:12–7.28231493
Adams ML, Jason LA, Pokorny S, Hunt Y. The relationship between school policies and youth tobacco use. Journal of School Health 2009;79(1):17–23.19149781
Add Health. About Add Health, n.d.; <https://addhealth.cpc.unc.edu/about/>; accessed: June 2, 2022.
Agaku IT, Ayo-Yusuf OA, Vardavas CI, Alpert HR, Connolly GN. Use of conventional and novel smokeless tobacco products among U.S. adolescents. Pediatrics 2013;132(3):e578–e586.23918889
Agaku IT, Perks SN, Odani S, Glover-Kudon R. Associations between public e-cigarette use and tobacco-related social norms among youth. Tobacco Control 2020;29(3):332–40.31110159
Al-Omari H, Scheibmeir M. Arab Americans’ acculturation and tobacco smoking. Journal of Transcultural Nursing 2009;20(2):227–33.19346414
Albertsen K, Borg V, Oldenburg B. A systematic review of the impact of work environment on smoking cessation, relapse and amount smoked. Preventive Medicine 2006;43(4):291–305.16787657
Albertsen K, Hannerz H, Borg V, Burr H. Work environment and smoking cessation over a five-year period. Scandinavian Journal of Public Health 2004;32(3):164–71.15204176
Alexander AC, Robinson LA, Ward KD, Farrell AS, Ferkin AC. Religious beliefs against smoking among black and white urban youth. Journal of Religion and Health 2016;55(6):1907–16.26510855
Allard KO, Thomsen JF, Mikkelsen S, Rugulies R, Mors O, Kaergaard A, Kolstad HA, Kaerlev L, Andersen JH, Hansen AM, . Effects of psychosocial work factors on lifestyle changes: a cohort study. Journal of Occupational and Environmental Medicine 2011;53(12):1364–71.22104976
Ambrose BK, Day HR, Rostron B, Conway KP, Borek N, Hyland A, Villanti AC. Flavored tobacco product use among U.S. youth aged 12–17 years, 2013–2014. JAMA: the Journal of the American Medical Association 2015;314(17):1871–3.26502219
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 5th ed. Arlington (VA): American Psychiatric Association, 2013.
Amin V, Lhila A. Decomposing racial differences in adolescent smoking in the U.S. Economics and Human Biology 2016;22:161–76.27213297
Anderson AR, Wu J. Top five industries resulting in injuries from acute chemical incidents—Hazardous Substance Emergency Events Surveillance, nine states, 1999–2008. Morbidity and Mortality Weekly Report Supplements 2015;64(2):47–53.25856538
Angus K, Semple S. Home health and community care workers’ occupational exposure to secondhand smoke: a rapid literature review. Nicotine & Tobacco Research 2019;21(12):1673–9.30365035
Arku RE, Adamkiewicz G, Vallarino J, Spengler JD, Levy DE. Seasonal variability in environmental tobacco smoke exposure in public housing developments. Indoor Air 2015;25(1):13–20.24750252
Asbridge M, Tanner J, Wortley S. Ethno-specific patterns of adolescent tobacco use and the mediating role of acculturation, peer smoking, and sibling smoking. Addiction 2005;100(9):1340–51.16128723
Assari S, Bazargan M. Second-hand smoke exposure at home in the United States; minorities’ diminished returns. International Journal of Travel Medicine and Global Health 2019;7(4):135–41.32195278
Azagba S, Shan L, Manzione L. Associations of home and workplace vaping restrictions with e-cigarette use among U.S. adults. Preventive Medicine 2020;139:106196.32653356
Azagba S, Sharaf MF. The effect of job stress on smoking and alcohol consumption. Health Economics Review 2011;1(1):15.22827918
Babb S, Liu B, Kenemer B, Holmes CB, Hartman AM, Gibson JT, King BA. Changes in self-reported smoke-free workplace policy coverage among employed adults—United States, 2003 and 2010–2011. Nicotine & Tobacco Research 2018;20(11):1327–35.29059420
Babb S, Malarcher A, Asman K, Johns M, Caraballo R, VanFrank B, Garrett B. Disparities in cessation behaviors between Hispanic and non-Hispanic White adult cigarette smokers in the United States, 2000–2015. Preventing Chronic Disease 2020;17:E10.31999539
Babb S, Malarcher A, Schauer G, Asman K, Jamal A. Quitting smoking among adults—United States, 2000–2015. Morbidity and Mortality Weekly Report 2017;65:1457–64.28056007
Bacio GA, Estrada Y, Huang S, Martinez M, Sardinas K, Prado G. Ecodevelopmental predictors of early initiation of alcohol, tobacco, and drug use among Hispanic adolescents. Journal of School Psychology 2015;53(3):195–208.26054814
Bailey SR, Heintzman J, Jacob RL, Puro J, Marino M. Disparities in smoking cessation assistance in U.S. primary care clinics. American Journal of Public Health 2018;108(8):1082–90.29927641
Bannai A, Tamakoshi A. The association between long working hours and health: a systematic review of epidemiological evidence. Scandinavian Journal of Work, Environment, & Health 2014;40(1):5–18.
Barbeau EM, Krieger N, Soobader MJ. Working class matters: socioeconomic disadvantage, race/ethnicity, gender, and smoking in NHIS 2000. American Journal of Public Health 2004;94(2):269–78.14759942
Barnoya J, Glantz SA. Cardiovascular effects of secondhand smoke: nearly as large as smoking. Circulation 2005;111(20):2684–98.15911719
Barrington-Trimis JL, Braymiller JL, Unger JB, McConnell R, Stokes A, Leventhal AM, Sargent JD, Samet JM, Goodwin RD. Trends in the age of cigarette smoking initiation among young adults in the U.S. from 2002 to 2018. JAMA Network Open 2020;3(10):e2019022.33021650
Barrington-Trimis JL, Samet JM, McConnell R. Flavorings in electronic cigarettes: an unrecognized respiratory health hazard? JAMA: the Journal of the American Medical Association 2014;312(23):2493–4.25383564
Battle RS, Cunradi CB, Moore RS, Yerger VB. Smoking cessation among transit workers: beliefs and perceptions among an at-risk occupational group. Substance Abuse Treatment, Prevention, and Policy 2015;10(1):19.25962517
Bello MS, Liautaud MM, De La Cerda JT, Pang RD, Ray LA, Ahluwalia JA, Leventhal AM. Association of frequency of perceived exposure to discrimination with tobacco withdrawal symptoms and smoking lapse behavior in African Americans. Addiction 2021;116(4):914–25.32860477
Benner AD, Wang Y. Adolescent substance use: the role of demographic marginalization and socioemotional distress. Developmental Psychology 2015;51(8):1086–97.26075631
Berchick E, Barnett J, Upton R. Health insurance coverage in the United States: 2018. Washington (DC): U.S. Government Printing Office, 2019.
Berdahl TA. Racial/ethnic and gender differences in individual workplace injury risk trajectories: 1988–1998. American Journal of Public Health 2008;98(12):2258–63.18235072
Berg CJ, Daley CM, Nazir N, Cully A, Pacheco CM, Buchanan T, Ahuwalia JS, Greiner KA, Choi WS. Smoke-free policies in the workplace and in the home among American Indians. Journal of Health Disparities, Research, and Practice 2012;5(2):7.24286021
Berry JW. Immigration, acculturation, and adaptation. Applied Psychology 1997;46(1):5–34.
Berry JW. Conceptual approaches to acculturation. In: Chun KM, Balls Organista P, Marin G, editors. Acculturation: Advances in Theory, Measurement, and Applied Research. Washington (DC): American Psychological Association, 2003:17–37.
Berry JW, Phinney JS, Sam DL, Vedder P. Immigrant youth: acculturation, identity, and adaptation. Applied Psychology 2006;55(3):303–32.
Berry JW, Phinney JS, Sam DL, Vedder P, editors. Immigrant Youth in Cultural Transition: Acculturation, Identity and Adaptation Across National Contexts. Mahwah (NJ): Lawrence Erlbaum Associates, 2022.
Bersamin M, Paschall MJ, Fisher DA. School-based health centers and adolescent substance use: moderating effects of race/ethnicity and socioeconomic status. Journal of School Health 2017;87(11):850–7.29023835
Bethel JW, Schenker MB. Acculturation and smoking patterns among Hispanics: a review. American Journal of Preventive Medicine 2005;29(2):143–8.16005811
Blank MD, Ozga JE, Romm KF, Douglas A, Alexander L, Doogan NJ, Wilson M, Dino G. Geographic isolation predicts tobacco product use among youth: a latent class analysis. Journal of Rural Health 2022;38(2):373–81.
Blosnich JR, Horn K. Associations of discrimination and violence with smoking among emerging adults: differences by gender and sexual orientation. Nicotine & Tobacco Research 2011;13(12):1284–95.21994344
Boal WL, Li J, Sussell A. Health insurance coverage by occupation among adults aged 18–64 years—17 states, 2013–2014. Morbidity and Mortality Weekly Report 2018;67(21):593–8.29851945
Bohnert KM, Rios-Bedoya CF, Breslau N. Parental monitoring at age 11 and smoking initiation up to age 17 among Blacks and Whites: a prospective investigation. Nicotine & Tobacco Research 2009;11(12):1474–8.19897527
Bonell C, Blakemore SJ, Fletcher A, Patton G. Role theory of schools and adolescent health. Lancet Child Adolescent Health 2019;3(10):742–8.31303445
Bonell C, Fletcher A, Jamal F, Aveyard P, Markham W. Where next with theory and research on how the school environment influences young people’s substance use? Health & Place 2016;40:91–7.27232064
Bonell C, Fletcher A, Jamal F, Wells H, Harden A, Murphy S, Thomas J. Theories of how the school environment impacts on student health: Systematic review and synthesis. Health & Place 2013;24:242–9.24177419
Booker KC. School belonging and the African American adolescent: what do we know and where should we go? The High School Journal 2006;89(4):1–7.
Boris NW, Johnson CC, Huang S, Myers L, Andrew K, Webber LS. Targeting school tobacco policy: lessons from the Acadiana Coalition of Teens Against Tobacco (ACTT). Health Promotion Practice 2009;10(4):549–56.18367640
Boyko EJ, Trone DW, Peterson AV, Jacobson IG, Littman AJ, Maynard C, Seelig AD, Crum-Cianflone NF, Bricker JB. Longitudinal investigation of smoking initiation and relapse among younger and older U.S. military personnel. American Journal of Public Health 2015;105(6):1220–9.25880953
Brener ND, Demissie Z, McManus T, Shanklin SL, Queen B, Kann L. School Health Profiles 2016: Characteristics of Health Programs Among Secondary Schools. Atlanta (GA): Centers for Disease Control and Prevention, 2017.
Brissette I, Fisher B, Spicer DA, King L. Worksite characteristics and environmental and policy supports for cardiovascular disease prevention in New York state. Preventing Chronic Disease 2008;5(2):A37.18341773
Brisson C, Larocque B, Moisan J, Vezina M, Dagenais GR. Psychosocial factors at work, smoking, sedentary behavior, and body mass index: a prevalence study among 6,995 white collar workers. Journal of Occupational and Environmental Medicine 2000;42(1):40–6.10652687
Brondolo E, Monge A, Agosta J, Tobin JN, Cassells A, Stanton C, Schwartz J. Perceived ethnic discrimination and cigarette smoking: examining the moderating effects of race/ethnicity and gender in a sample of Black and Latino urban adults. Journal of Behavioral Medicine 2015;38(4):689–700.26054448
Brook JS, Brook DW, Balka EB, Rosenberg G. Predictors of rebellious behavior in childhood parental drug use, peers, school environment, and child personality. Journal of Addictive Diseases 2006;25(2):77–87.16785223
Brook JS, Zhang C, Finch SJ, Brook DW. Adolescent pathways to adult smoking: ethnic identity, peer substance use, and antisocial behavior. American Journal on Addictions 2010;19(2):178–86.20163390
Brown JM, Anderson Goodell EM, Williams J, Bray RM. Socioecological risk and protective factors for smoking among active duty U.S. military personnel. Military Medicine 2018;183(7–8):e231–e239.29697835
Brown QL, Hasin DS, Keyes KM, Fink DS, Ravenell O, Martins SS. Health insurance, alcohol and tobacco use among pregnant and non-pregnant women of reproductive age. Drug and Alcohol Dependence 2016;166:116–24.27422762
Brown R, Evans WP. Extracurricular activity and ethnicity: creating greater school connection among diverse student populations. Urban Education 2002;37(1):41–58.
Browning KK, Ferketich AK, Salsberry PJ, Wewers ME. Socioeconomic disparity in provider-delivered assistance to quit smoking. Nicotine & Tobacco Research 2008;10(1):55–61.18188745
Buettner-Schmidt K, Miller DR, Maack B. Disparities in rural tobacco use, smoke-free policies, and tobacco taxes. Western Journal of Nursing Research 2019;41(8):1184–202.30774036
Cantrell J, Bennett M, Mowery P, Xiao H, Rath J, Hair E, Vallone D. Patterns in first and daily cigarette initiation among youth and young adults from 2002 to 2015. PLoS One 2018;13(8):e0200827.30096141
Castellan RM, Chosewood LC, Trout D, Wagner GR, Caruso CC, Mazurek J, McCrone SH, Weissman DN. Promoting Health and Preventing Disease and Injury through Workplace Tobacco Policies. Current Intelligence Bulletin 67, 2015; <https://www.cdc.gov/niosh/docs/2015-113/pdfs/FY15_CIB-67_2015-113_v3.pdf?id=10.26616/NIOSHPUB2015113>; accessed: April 16, 2020.
Castro Y, Bares CB, Castillo B, Kennedy A. Sociodemographics, but not acculturation proxies, account for differences in lifetime cessation between white and Hispanic smokers. Ethnicity & Disease 2018;28(3):145–52.30038475
Castro Y, Reitzel LR, Businelle MS, Kendzor DE, Mazas CA, Li Y, Cofta-Woerpel L, Wetter DW. Acculturation differentially predicts smoking cessation among Latino men and women. Cancer Epidemiology, Biomarkers & Prevention 2009;18(12):3468–75.
Castro Y, Vinci C, Heppner WL, Cano MA, CorreaFernandez V, Wetter DW. Revisiting the relationship between acculturation and smoking cessation among Mexican Americans. Annals of Behavioral Medicine 2019;53(3):211–22.29746621
Cengelli S, O’Loughlin J, Lauzon B, Cornuz J. A systematic review of longitudinal population-based studies on the predictors of smoking cessation in adolescent and young adult smokers. Tobacco Control 2012;21(3):355–62.21846777
Center on Budget and Policy Priorities. 2017 Federal Rental Assistance Factsheets Sources and Methodology, March 31, 2017; <https://www.cbpp.org/research/2017-federal-rental-assistance-factsheets-sources-and-methodology>; accessed: February 11, 2019.
Centers for Disease Control and Prevention. Vital signs: current cigarette smoking among adults aged ≥18 years with mental illness—United States, 2009–2011. Morbidity and Mortality Weekly Report 2013;62:81–7.23388551
Centers for Disease Control and Prevention. Best Practices User Guide: Health Equity in Tobacco Prevention and Control. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2015.
Centers for Disease Control and Prevention. STATE System Medicaid coverage of tobacco cessation treatments fact sheet, August 5, 2022; <https://www.cdc.gov/statesystem/factsheets/medicaid/Cessation.html>; accessed: October 3, 2022.
Chavez LJ, Ornelas IJ, Lyles CR, Williams EC. Racial/ethnic workplace discrimination: association with tobacco and alcohol use. American Journal of Preventive Medicine 2015;48(1):42–9.25441232
Chen J, Vargas-Bustamante A, Mortensen K, Ortega AN. Racial and ethnic disparities in health care access and utilization under the Affordable Care Act. Medical Care 2016;54(2):140–6.26595227
Chen ZM, Xu Z, Collins R, Li WX, Peto R. Early health effects of the emerging tobacco epidemic in China. A 16-year prospective study. JAMA: the Journal of the American Medical Association 1997;278(18):1500–4.9363969
Cheng KW, Glantz SA, Lightwood JM. Association between smokefree laws and voluntary smokefreehome rules. American Journal of Preventive Medicine 2011;41(6):566–72.22099232
Cheng KW, Liu F, Gonzalez M, Glantz S. The effects of workplace clean indoor air law coverage on workers’ smoking-related outcomes. Health Economics 2017;26(2):226–42.26639369
Cheng KW, Okechukwu CA, McMillen R, Glantz SA. Association between clean indoor air laws and voluntary smokefree rules in homes and cars. Tobacco Control 2015;24(2):168–74.24114562
Chin J, Lustik MB, Pflipsen M. Prevalence of use and perceptions of electronic smoking devices in a U.S. Army infantry division. Military Medicine 2018;183(1–2):e127–e33.29401340
Choi S, Rankin S, Stewart A, Oka R. Effects of acculturation on smoking behavior in Asian Americans: a meta-analysis. Journal of Cardiovascular Nursing 2008;23(1):67–73.18158512
Christiansen BA, Macmaster DR, Heiligenstein EL, Glysch RL, Riemer DM, Adsit RT, Hayden KA, Hollenback CP, Fiore MC. Measuring the integration of tobacco policy and treatment into the behavioral health care delivery system: how are we doing? Journal of Health Care for the Poor and Underserved 2016;27(2):510–26.27180692
Clougherty JE, Souza K, Cullen MR. Work and its role in shaping the social gradient in health. Annals of the New York Academy of Sciences 2010;1186(1):102–24.20201870
Cohen J. Statistical Power Analysis for the Behavioral Sciences. 2nd ed. Mahwah (NJ): Lawrence Erlbaum Associates, 1988.
Cokkinides VE, Halpern MT, Barbeau EM, Ward E, Thun MJ. Racial and ethnic disparities in smoking-cessation interventions: analysis of the 2005 National Health Interview Survey. American Journal of Preventive Medicine 2008;34(5):404–12.18407007
Comiford A, Garroutte E, Barbosa-Leiker C, Chen S, McDonell M. Prevalence and indicators of household smoking bans among American Indians. Journal of Community Health 2018;43(4):746–55.29427130
Cornelius ME, Wang TW, Jamal A, Loretan CG, Neff LJ. Tobacco product use among adults—United States, 2019. Morbidity and Mortality Weekly Report 2020;69(46):1736–42.33211681
Corona R, Turf E, Corneille MA, Belgrave FZ, Nasim A. Risk and protective factors for tobacco use among 8th- and 10th-grade African American students in Virginia. Preventing Chronic Disease 2009;6(2):A45.19288988
Corrao MA, Guindon GE, Cokkinides V, Sharma N. Building the evidence base for global tobacco control. Bulletin of the World Health Organization 2000;78(7):884–90.10994261
Coulter RWS, Bersamin M, Russell ST, Mair C. The effects of gender- and sexuality-based harassment on lesbian, gay, bisexual, and transgender substance use disparities. Journal of Adolescent Health 2018;62(6):688–700.
Creamer MR, Wang TW, Babb S, Cullen KA, Day H, Willis G, Ahmed Jamal A, Neff L. Tobacco product use and cessation indicators among adults—United States, 2018. Morbidity and Mortality Weekly Report 2019;68(45):1013–9.
Crossnohere NL, Davey-Rothwell M, Latkin C, Tseng TY, Czaplicki L, Knowlton A. The interaction of smoking cessation norms and nicotine dependence on quit attempts: gender-stratified results for low-income smokers in Baltimore, MD. Substance Use & Misuse 2020;55(3):424–8.31729269
Cunradi CB, Lipton R, Banerjee A. Occupational correlates of smoking among urban transit operators: a prospective study. Substance Abuse Treatment, Prevention, and Policy 2007;2:36.18096082
Cunradi CB, Moore RS, Battle RS. Prevalence and correlates of current and former smoking among urban transit workers. Safety and Health at Work 2017;8(4):402–6.29276641
Czoli CD, Hammond D, White CM. Electronic cigarettes in Canada: prevalence of use and perceptions among youth and young adults. Canadian Journal of Public Health 2014;105(2):e97–e102.24886856
Dai H. Youth observation of e-cigarette use in or around school, 2019. American Journal of Preventive Medicine 2021;60(2):241–9.33353794
Darling-Hammond L. Inequality and school resources: what it will take to close the opportunity gap. In: Carter PL, Welner KG, editors. Closing the Opportunity Gap: What America Must Do to Give Every Child an Even Chance. New York (NY): Oxford University Press, 2013:77–97.
Darling N, Caldwell LL, Smith R. Participation in school-based extracurricular activities and adolescent adjustment. Journal of Leisure Research 2005;37(1):51–76.
Day JK, Fish JN, Perez-Brumer A, Hatzenbuehler ML, Russell ST. Transgender youth substance use disparities: results from a population-based sample. Journal of Adolescent Health 2017;61(6):729–35.
Deitch CH, Huffman ML. Family-responsive benefits and the two-tiered labor market. In: Hertz R, Marshall NL, editors. Working Families: The Transformation of the American Home. Berkeley (CA): University of California Press, 2001:103–30.
Diaz JD. School attachment among Latino youth in rural Minnesota. Hispanic Journal of Behavioral Sciences 2016;27(3):300–18.
DiGiulio A, Jump Z, Babb S, Schecter A, Williams KS, Yembra D, Armour BS. State Medicaid coverage for tobacco cessation treatments and barriers to accessing treatments—United States, 2008–2018. Morbidity and Mortality Weekly Report 2020;69(6):155–60.32053583
Dornbusch SM, Erickson KG, Laird J, Wong CA. The relation of family and school attachment to adolescent deviance in diverse groups and communities. Journal of Adolescent Research 2016;16(4):396–422.
Dotterer AM, McHale SM, Crouter AC. Sociocultural factors and school engagement among African American youth: the roles of racial discrimination, racial socialization and ethnic identity. Applied Developmental Science 2009;13(2):51–73.27134516
Dutra LM, Glantz SA, Lisha NE, Song AV. Beyond experimentation: Five trajectories of cigarette smoking in a longitudinal sample of youth. PLoS One 2017;12(2):e0171808.28182748
Emory K, Saquib N, Gilpin EA, Pierce JP. The association between home smoking restrictions and youth smoking behaviour: a review. Tobacco Control 2010;19(6):495–506.20852326
Eriksen W. Work factors and smoking cessation in nurses’ aides: a prospective cohort study. BMC Public Health 2005;5:142.16379672
Fechter-Leggett ED, White SK, Fedan KB, Cox-Ganser JM, Cummings KJ. Burden of respiratory abnormalities in microwave popcorn and flavouring manufacturing workers. Occupational and Environmental Medicine 2018;75(10):709–15.30045951
Federal Register. Office of the Assistant Secretary for Public and Indian Housing, U.S. Department of Housing and Urban Development. Instituting smoke-free public housing, 81 Fed. Reg. 87430 (2016); <https://www.federalregister.gov/documents/2016/12/05/2016-28986/instituting-smoke-free-public-housing>; accessed: April 20, 2020.
Fernander A, Schumacher M, Nasim A. Sociocultural stress, smoking risk, and cessation among African American women. Journal of Black Psychology 2008;34(1):49–69.
Fielding-Singh P, Vogel EA, Prochaska JJ. Occupying multiple stigmatized identities: smoking and unemployment stigmas among the unemployed. SSM Population Health 2020;11:100598.32490137
Fiore MC, Bailey WC, Cohen SJ, Dorfman SF, Goldstein MG, Gritz ER, Heyman RB, Jaen CR, Kottke TE, Lando HA, et al. Treating Tobacco Use and Dependence: Clinical Practice Guideline. Rockville (MD): U.S. Department of Health and Human Services, 2000.
Fiore MC, Jaén CR, Baker TB, Bailey WC, Benowitz NL, Curry SJ, Dorfman SF, Froelicher ES, Goldstein MG, Healton CG, et al. Treating Tobacco Use and Dependence: 2008 Update. U.S. Public Health Service Clinical Practice Guideline. Rockville (MD): U.S. Department of Health and Human Services, 2008.
Fletcher A, Bonell C. Social network influences on smoking, drinking and drug use in secondary school: centrifugal and centripetal forces. Sociology of Health and Illness 2013;35(5):699–715.23009704
Flynn MA, Cunningham TR, Guerin RJ, Keller B, Chapman LJ, Hudson D, Salgado C. Overlapping Vulnerabilities: the Occupational Safety and Health of Young Workers in Small Construction Firms, May 2015; <https://www.cdc.gov/niosh/docs/2015-178/pdfs/2015-178.pdf?id=10.26616/NIOSHPUB2015178>; accessed: May 17, 2023.
Foli KJ, Zhang L, Reddick B. Predictors of substance use in registered nurses: The role of psychological trauma. Western Journal of Nursing Research 2021:193945920987123.
Fredricks JA, Eccles JS. Breadth of extracurricular participation and adolescent adjustment among AfricanAmerican and European-American youth. Journal of Research on Adolescence 2010;20(2):307–33.22837637
Friedman AS, Schpero WL, Busch SH. Evidence suggests that the ACA’s tobacco surcharges reduced insurance take-up and did not increase smoking cessation. Health Affairs 2016;35(7):1176–83.27385231
Fu SS, Sherman SE, Yano EM, van Ryn M, Lanto AB, Joseph AM. Ethnic disparities in the use of nicotine replacement therapy for smoking cessation in an equal access health care system. American Journal of Health Promotion 2005;20(2):108–16.16295702
Galanti MR, Coppo A, Jonsson E, Bremberg S, Faggiano F. Anti-tobacco policy in schools: upcoming preventive strategy or prevention myth? A review of 31 studies. Tobacco Control 2014;23(4):295–301.23716172
Garrett BE, Gardiner PS, Wright LT, Pechacek TF. The African American youth smoking experience: an overview. Nicotine & Tobacco Research 2016;18 (Suppl 1):S11–S15.26980860
Garrusi B, Nakhaee N. Religion and smoking: a review of recent literature. International Journal of Psychiatry in Medicine 2012;43(3):279–92.22978085
Gebrekristos HT. Health inequalities among sexual minority youth: a need for sexual orientation and gender expression sensitive school environment. Sexually Transmitted Infections 2012;88(4):236–7.22436197
Geller AC, Rees VW, Brooks DR. The proposal for smoke-free public housing: benefits, challenges, and opportunities for 2 million residents. JAMA: the Journal of the American Medical Association 2016;315(11):1105–6.26882206
Gentzke AS, Creamer M, Cullen KA, Ambrose BK, Willis G, Jamal A, King BA. Vital signs: tobacco product use among middle and high school students—United States, 2011–2018. Morbidity and Mortality Weekly Report 2019;68:157–64.30763302
Gentzke AS, Homa DM, Kenemer JB, Gomez Y, King BA. Rules to prohibit the use of electronic vapor products inside homes and personal vehicles among adults in the U.S., 2017. Preventive Medicine 2018a;114:47–53.29857024
Gentzke AS, Hyland A, Kiviniemi M, Travers MJ. Attitudes and experiences with secondhand smoke and smoke-free policies among subsidised and market-rate multiunit housing residents living in six diverse communities in the USA. Tobacco Control 2018b;27(2):194–202.28302920
Gentzke AS, Wang TW, Cornelius M, Park-Lee E, Ren C, Sawdey MD, Cullen KA, Loretan C, Jamal A, Homa DM. Tobacco product use and associated factors among middle and high school students—National Youth Tobacco Survey, United States, 2021. Morbidity and Mortality Weekly Report Surveillance Summaries 2022;71(5):1–29.
Gentzke AS, Wang TW, Jamal A, Park-Lee E, Ren C, Cullen KA, Neff L. Tobacco product use among middle and high school students—United States, 2020. Morbidity and Mortality Weekly Report 2020;69(50):1881–8.33332300
Gerrard M, Gibbons FX, Stock ML, Lune LS, Cleveland MJ. Images of smokers and willingness to smoke among African American pre-adolescents: an application of the prototype/willingness model of adolescent health risk behavior to smoking initiation. Journal of Pediatric Psychology 2005;30(4):305–18.15863428
Giovino G, Pederson L, Trosclair A. The Prevalence of Selected Cigarette Smoking Behaviors by Occupational Class in the United States. Paper presented at Work, Smoking, and Health: A NIOSH Scientific Workshop; June 15–16, 2000; Washington (DC).
Gonzales M, Malcoe LH, Kegler MC, Espinoza J. Prevalence and predictors of home and automobile smoking bans and child environmental tobacco smoke exposure: a cross-sectional study of U.S.- and Mexico-born Hispanic women with young children. BMC Public Health 2006;6:265.17069652
Gonzalez M, Sanders-Jackson A, Song AV, Cheng KW, Glantz SA. Strong smoke-free law coverage in the United States by race/ethnicity: 2000–2009. American Journal of Public Health 2013;103(5):e62–e66.23488507
Gotay CC, Reid MS, Dawson MY, Wang S. Acculturation and smoking in North Americans of Chinese ancestry: a systematic review. Canadian Journal of Public Health 2015;106(5):e333–e340.26451998
Green KL, Johnson JV. The effects of psychosocial work organization on patterns of cigarette smoking among male chemical plant employees. American Journal of Public Health 1990;80(11):1368–71.2240307
Greenlund KJ, Liu K, Knox S, McCreath H, Dyer AR, Gardin J. Psychosocial work characteristics and cardiovascular disease risk factors in young adults: the CARDIA study. Coronary Artery Risk Disease in Young Adults. Social Science & Medicine 1995;41(5):717–23.7502103
Griep RH, Nobre AA, Guimarães de Mello Alves M, Mendes da Fonseca M, Cardoso L, Giatti L, Melo E, Toivanen S, Chor D. Job strain and unhealthy lifestyle: results from the baseline cohort study, Brazilian Longitudinal Study of Adult Health (ELSA-Brasil). BMC Public Health 2015;15(309).
Griesler PC, Kandel DB, Davies M. Ethnic differences in predictors of initiation and persistence of adolescent cigarette smoking in the National Longitudinal Survey of Youth. Nicotine & Tobacco Research 2002;4(1):79–93.11906684
Groom AL, Vu TT, Landry RL, Kesh A, Hart JL, Walker KL, Wood LA, Robertson RM, Payne TJ. The influence of friends on teen vaping: a mixed-methods approach. International Journal of Environmental Research and Public Health 2021;18(13):6784.34202600
Guevarra JS, Kwate NO, Tang TS, Valdimarsdottir HB, Freeman HP, Bovbjerg DH. Acculturation and its relationship to smoking and breast self-examination frequency in African American women. Journal of Behavioral Medicine 2005;28(2):191–9.15957574
Gutman LM, Eccles JS, Peck S, Malanchuk O. The influence of family relations on trajectories of cigarette and alcohol use from early to late adolescence. Journal of Adolescence 2011;34(1):119–28.20129658
Haardörfer R, Kreuter M, Berg CJ, Escoffery C, Bundy LT, Hovell M, Mullen PD, Williams R, Kegler MC. Cessation and reduction in smoking behavior: impact of creating a smoke-free home on smokers. Health Education Research 2018;33(3):256–9.29788227
Haenszel W, Shimkin MB, Miller HP. Tobacco smoking patterns in the United States. Public Health Monograph 1956;45:1–105.13408401
Hahn EJ, Rayens MK, Rasnake R, York N, Okoli CT, Riker CA. School tobacco policies in a tobacco-growing state. Journal of School Health 2005;75(6):219–25.16014128
Hall M, Fullerton L, FitzGerald C, Green D. Suicide risk and resiliency factors among Hispanic teens in New Mexico: schools can make a difference. Journal of School Health 2018a;88(3):227–36.29399842
Hall MT, Austin RP, Do TA, McGlynn A. Vape and aviate: electronic-cigarette use and misuse in naval aviation. Military Medicine 2018b;183(3–4):e165–e70.29365191
Hall SM, Prochaska JJ. Treatment of smokers with cooccurring disorders: emphasis on integration in mental health and addiction treatment settings. Annual Review of Clinical Psychology 2009;5:409–31.
Hamilton CJ, Mahalik JR. Minority stress, masculinity, and social norms predicting gay men’s health risk behaviors. Journal of Counseling Psychology 2009;56(1):132–41.
Han B, Volkow ND, Blanco C, Tipperman D, Einstein EB, Compton WM. Trends in prevalence of cigarette smoking among U.S. adults with major depression or substance use disorders, 2006–2019. JAMA: the Journal of the American Medical Association 2022;327(16):1566–76.35471512
Harris JK, Geremakis C, Moreland-Russell S, Carothers BJ, Kariuki B, Shelton SC, Kuhlenbeck M. Demographic and geographic differences in exposure to secondhand smoke in Missouri workplaces, 2007–2008. Preventing Chronic Disease 2011;8(6):A135.22005628
Hatchel T, Marx R. Understanding intersectionality and resiliency among transgender adolescents: exploring pathways among peer victimization, school belonging, and drug use. International Journal of Environmental Research and Public Health 2018;15(6):E1289.
Hatzenbuehler ML, Flores AR, Gates GJ. Social attitudes regarding same-sex marriage and LGBT health disparities: results from a national probability sample. Journal of Social Issues 2017;73(3):508–28.
Hatzenbuehler ML, Jun HJ, Corliss HL, Austin SB. Structural stigma and cigarette smoking in a prospective cohort study of sexual minority and heterosexual youth. Annals of Behavioral Medicine 2014;47(1):48–56.24136092
Hatzenbuehler ML, McLaughlin KA, Xuan Z. Social networks and sexual orientation disparities in tobacco and alcohol use. Journal of Studies on Alcohol and Drugs 2015;76(1):117–26.25486400
Hawkins JD, Weis JG. The social development model: An integrated approach to delinquency prevention. Journal of Primary Prevention 1985;6(2):73–97.24271382
Heikkila K, Nyberg ST, Fransson EI, Alfredsson L, De Bacquer D, Bjorner JB, Bonenfant S, Borritz M, Burr H, Clays E, . Job strain and tobacco smoking: an individual-participant data meta-analysis of 166,130 adults in 15 European studies. PLoS One 2012;7(7):e35463.22792154
Hellerstedt WL, Jeffery RW. The association of job strain and health behaviours in men and women. International Journal of Epidemiology 1997;26(3):575–83.9222783
Hermes ED, Wells TS, Smith B, Boyko EJ, Gackstetter GG, Miller SC, Smith TC. Smokeless tobacco use related to military deployment, cigarettes and mental health symptoms in a large, prospective cohort study among U.S. service members. Addiction 2012;107(5):983–94.22126651
Hoffman BR, Sussman S, Unger JB, Valente TW. Peer influences on adolescent cigarette smoking: a theoretical review of the literature. Substance Use & Misuse 2006;41(1):103–55.16393739
Holt CL, Roth DL, Huang J, Clark EM. Gender differences in the roles of religion and locus of control on alcohol use and smoking among African Americans. Journal of Studies on Alcohol and Drugs 2015;76(3):482–92.25978836
Homa DM, Neff LJ, King BA, Caraballo RS, Bunnell RE, Babb SD, Garrett BE, Sosnoff CS, Wang L. Vital signs: disparities in nonsmokers’ exposure to secondhand smoke—United States, 1999–2012. Morbidity and Mortality Weekly Report 2015;64(4):103–8.25654612
Hong T, Rice J, Johnson C. Ethnic group and temporal influences of social norms: smoking behavior among a panel of adolescents. Journal of Communication 2012;62(1):158–74.
Horton KD, Loukas A. Discrimination, religious coping, and tobacco use among White, African American, and Mexican American vocational school students. Journal of Religion and Health 2013;52(1):169–83.21249522
Huebner DM, Thoma BC, Neilands TB. School victimization and substance use among lesbian, gay, bisexual, and transgender adolescents. Prevention Science 2015;16(5):734–43.25529390
Hughes MC, Yette EM, Hannon PA, Harris JR, Tran NM, Reid TR. Promoting tobacco cessation via the workplace: opportunities for improvement. Tobacco Control 2011;20(4):305–8.21377998
Hunt JJ, Gajewski BJ, Jiang Y, Cupertino AP, Richter KP. Capacity of U.S. drug treatment facilities to provide evidence-based tobacco treatment. American Journal of Public Health 2013;103(10):1799–801.23948006
Hurtado DA, Okechukwu CA, Buxton OM, Hammer L, Hanson GC, Moen P, Klein LC, Berkman LF. Effects on cigarette consumption of a work-family supportive organisational intervention: 6-month results from the work, family and health network study. Journal of Epidemiology and Community Health 2016;70(12):1155–61.27225680
Hurtado DA, Sabbath EL, Ertel KA, Buxton OM, Berkman LF. Racial disparities in job strain among American and immigrant long-term care workers. International Nursing Review 2012;59(2):237–44.22591096
Husten CG. A Call for ACTTION: Increasing access to tobacco-use treatment in our nation. American Journal of Preventive Medicine 2010;38(3 Suppl):S414–S417.20176316
IARC Working Group on the Evaluation of Carcinogenic Risks to Humans. IARC Monographs on the Evaluation of Carcinogenic Risks to Humans: Betel-Quid and Areca-Nut Chewing and Some Areca-Nut Derived Nitrosamines. Vol. 85. Lyon (France): International Agency for Research on Cancer, 2004.
Ispa-Landa S. Race, and justifications for group exclusion: urban Black students bussed to affluent suburban schools. Sociology of Education 2013;86(3):218–33.
Jackson A, Kong G, Wu R, Morean ME, Davis DR, Camenga DR, Cavallo DA, Bold KW, Simon P, Krishnan-Sarin S. E-cigarette devices used on school grounds. Addictive Behaviors 2020;110:106516.32622027
Jamal A, Dube SR, Malarcher AM, Shaw L, Engstrom MC. Tobacco use screening and counseling during physician office visits among adults—National Ambulatory Medical Care Survey and National Health Interview Survey, United States, 2005–2009. Morbidity and Mortality Weekly Report Supplement 2012;61(2):38–45.22695462
Jayawardhana J, Bolton HE, Gaughan M. The association between school tobacco control policies and youth smoking behavior. International Journal of Behavioral Medicine 2019;26(6):658–64.31741294
Jitnarin N, Poston WSC, Haddock CK, Jahnke SA, Day RS, Severson HH. Prevalence and correlates of late initiation of smokeless tobacco in U.S. firefighters. Nicotine & Tobacco Research 2017;20(1):130–4.27940900
Kaestle CE, Wiles BB. Targeting high-risk neighborhoods for tobacco prevention education in schools. American Journal of Public Health 2010;100(9):1708–13.20019323
Kandel D, Schaffran C, Hu MC, Thomas Y. Age-related differences in cigarette smoking among whites and African-Americans: evidence for the cross-over hypothesis. Drug and Alcohol Dependence 2011;118(2–3):280–7.21561724
Kandel DB, Griesler PC, Hu MC. Intergenerational patterns of smoking and nicotine dependence among U.S. adolescents. American Journal of Public Health 2015;105(11):e63–e72.
Kaper J, Wagena EJ, Willemsen MC, van Schayck CP. Reimbursement for smoking cessation treatment may double the abstinence rate: results of a randomized trial. Addiction 2005;100(7):1012–20.15955017
Kaplan CP, Nguyen TT, Weinberg V. Longitudinal study of smoking progression in Chinese and Vietnamese American adolescents. Asian Pacific Journal of Cancer Prevention 2008;9(2):335–41.18712987
Karasek R, Theorell T. Healthy Work: Stress, Productivity, and the Reconstruction of Working Life. New York (NY): Basic Books, 1990.
Kava CM, Harris JR, Gary Chan KC, Kohn MJ, Parrish AT, Hannon PA. Tobacco evidence-based practice implementation and employee tobacco-related outcomes at small low-wage worksites. Journal of Occupational and Environmental Medicine 2019;61(7):e312–e316.31022102
Kegler MC, Malcoe LH. Smoking restrictions in the home and car among rural Native American and white families with young children. Preventive Medicine 2002;35(4):334–42.12453710
Keisler-Starkey K, Bunch LN. Health Insurance Coverage in the United States: 2020. U.S. Census Bureau Current Population Reports, P60-274. Washington (DC): U.S. Government Publishing Office, 2021.
Keltner CH, Kao TC, Ahmed A, Mancuso JD. E-cigarette and dual product use as an emerging health threat to the U.S. military. Tobacco Prevention & Cessation 2021;7:43.34141958
Kendzor DE, Businelle MS, Reitzel LR, Rios DM, Scheuermann TS, Pulvers K, Ahluwalia JS. Everyday discrimination is associated with nicotine dependence among African American, Latino, and White smokers. Nicotine & Tobacco Research 2014;16(6):633–40.24302634
Keske RR, Rees VW, Behm I, Wadler BM, Geller AC. Second-hand smoke exposure and mitigation strategies among home visitation workers. Tobacco Control 2013;22(4):250–4.22184207
Kim AS, Ko HJ, Kwon JH, Lee JM. Exposure to secondhand smoke and risk of cancer in never smokers: a meta-analysis of epidemiologic studies. International Journal of Environmental Research and Public Health 2018;15(9):1981.30208628
Kim HH, Chun J. Analyzing multilevel factors underlying adolescent smoking behaviors: the roles of friendship network, family relations, and school environment. Journal of School Health 2018;88(6):434–43.29749004
King BA, Babb SD, Tynan MA, Gerzoff RB. National and state estimates of secondhand smoke infiltration among U.S. multiunit housing residents. Nicotine & Tobacco Research 2013a;15(7):1316–21.23248030
King BA, Dube SR, Homa DM. Smoke-free rules and secondhand smoke exposure in homes and vehicles among U.S. adults, 2009–2010. Preventing Chronic Disease 2013b;10:E79.23680508
King BA, Homa DM, Dube SR, Babb SD. Exposure to secondhand smoke and attitudes toward smoke-free workplaces among employed U.S. adults: findings from the National Adult Tobacco Survey. Nicotine & Tobacco Research 2014;16(10):1307–18.24812025
King BA, Travers MJ, Cummings KM, Mahoney MC, Hyland AJ. Secondhand smoke transfer in multiunit housing. Nicotine & Tobacco Research 2010;12(11):1133–41.20889473
Kisker EE, Brown RS. Do school-based health centers improve adolescents’ access to health care, health status, and risk-taking behavior? Journal of Adolescent Health 1996;18(5):335–43.
Klonoff EA, Landrine H. Acculturation and cigarette smoking among African American adults. Journal of Behavioral Medicine 1996;19(5):501–14.8904731
Klonoff EA, Landrine H. Acculturation and cigarette smoking among African Americans: replication and implications for prevention and cessation programs. Journal of Behavioral Medicine 1999;22(2):195–204.10374143
Klonoff EA, Landrine H. Revising and improving the African American Acculturation Scale. Journal of Black Psychology 2000;26(2):235–61.
Knopf JA, Finnie RK, Peng Y, Hahn RA, Truman BI, Vernon-Smiley M, Johnson VC, Johnson RL, Fielding JE, Muntaner C, . School-based health centers to advance health equity: a community guide systematic review. American Journal of Preventive Medicine 2016;51(1):114–26.27320215
Kondo KK, Rossi JS, Schwartz SJ, Zamboanga BL, Scalf CD. Acculturation and cigarette smoking in Hispanic women: a meta-analysis. Journal of Ethnicity in Substance Abuse 2016;15(1):46–72.26114872
Kong G, Morean ME, Cavallo DA, Camenga DR, KrishnanSarin S. Reasons for electronic cigarette experimentation and discontinuation among adolescents and young adults. Nicotine & Tobacco Research 2015;17(7):847–54.25481917
Kosciw JG, Clark CM, Truong NL, Zongrone AD. The 2019 National School Climate Survey: The Experiences of Lesbian, Gay, Bisexual, Transgender, and Queer Youth in Our Nation’s Schools. New York (NY): Gay, Lesbian and Straight Education Network, 2020.
Kraev TA, Adamkiewicz G, Hammond SK, Spengler JD. Indoor concentrations of nicotine in low-income, multi-unit housing: associations with smoking behaviours and housing characteristics. Tobacco Control 2009;18(6):438–44.19679890
Krieger N, Kaddour A, Koenen K, Kosheleva A, Chen JT, Waterman PD, Barbeau EM. Occupational, social, and relationship hazards and psychological distress among low-income workers: implications of the “inverse hazard law”. Journal of Epidemiology and Community Health 2011;65(3):260–72.20713372
Kruger J, Jama A, Homa DM, Babb SD, King BA. Smokefree home and vehicle rules by tobacco use status among U.S. adults. Preventive Medicine 2015;78:9–13.26092055
Ku L, Bruen BK, Steinmetz E, Bysshe T. Medicaid tobacco cessation: big gaps remain in efforts to get smokers to quit. Health Affairs 2016;35(1):62–70.26733702
Kumar R, O’Malley PM, Johnston LD, Laetz VB. Alcohol, tobacco, and other drug use prevention programs in U.S. schools: a descriptive summary. Prevention Science 2013;14(6):581–92.23404662
Landrine H, Corral I. Sociocultural correlates of cigarette smoking among African-American men versus women: implications for culturally specific cessation interventions. Journal of Health Psychology 2016;21(6):954–61.25104780
Landrine H, Corral I, Campbell KM. Racial disparities in healthcare provider advice to quit smoking. Preventive Medicine Reports 2018;10:172–5.29868363
Landrine H, Klonoff EA. The African American Acculturation Scale: development, reliability, and validity. Journal of Black Psychology 1994;20(2):104–27.
Landrine H, Klonoff EA. African-American Acculturation: Deconstructing Race and Reviving Culture. Thousand Oaks (CA): Sage Publications, 1996.
Landrine H, Klonoff EA, Corral I, Fernandez S, Roesch S. Conceptualizing and measuring ethnic discrimination in health research. Journal of Behavioral Medicine 2006;29(1):79–94.16470345
Latimore TL, Peguero AA, Popp AM, Shekarkhar Z, Koo DJ. School-based activities, misbehavior, discipline, and racial and ethnic disparities. Education and Urban Society 2017;50(5):403–34.
Lazarus R, Folkman S. Stress, Appraisal, and Coping. New York: Springer, 1984.
Lazarus RS, Launier R. Stress-related transactions between person and environment. In: Pervin LA, Lewis M, editors. Perspectives in Interactional Psychology. New York: Plenum Press, 1978:287–327.
Leath S, Mathews C, Harrison A, Chavous T. Racial identity, racial discrimination, and classroom engagement outcomes among Black girls and boys in predominantly Black and predominantly White school districts. American Educational Research Journal 2019;56(4):1318–52.
Lee DJ, Fleming LE, Arheart KL, LeBlanc WG, Caban AJ, Chung-Bridges K, Christ SL, McCollister KE, Pitman T. Smoking rate trends in U.S. occupational groups: the 1987 to 2004 National Health Interview Survey. Journal of Occupational and Environmental Medicine 2007;49(1):75–81.17215716
Leigh JP. Occupations, cigarette smoking, and lung cancer in the epidemiological follow-up to the NHANES I and the California Occupational Mortality Study. Bulletin of the New York Academy of Medicine 1996;73(2):370–97.8982527
Letri-Mann F, Denis-Vatant C, Vercherin P, Vergnon C, Pelissier C, Fontana L. Occupational risk factors of smoking relapse during the first 6 months following a hospital smoking cessation consultation. Archives des Maladies Professionnelles et de L Environnement 2016;77(1):3–9.
Li D, Shi H, Xie Z, Rahman I, McIntosh S, Bansal-Travers M, Winickoff JP, Drehmer JE, Ossip DJ. Home smoking and vaping policies among U.S. adults: results from the Population Assessment of Tobacco and Health (PATH) study, wave 3. Preventive Medicine 2020;139:106215.32693178
Li J, Newcombe R, Walton D. The use of, and attitudes towards, electronic cigarettes and self-reported exposure to advertising and the product in general. Australian and New Zealand Journal of Public Health 2014;38(6):524–8.25376856
Li K, Wen M. Substance use, age at migration, and length of residence among adult immigrants in the United States. Journal of Immigrant and Minority Health 2015;17(1):156–64.23925520
Li S, Delva J. Social capital and smoking among Asian American men: an exploratory study. American Journal of Public Health 2012;102(Suppl 2):S212–S221.22401511
Li Y, Lerner RM. Trajectories of school engagement during adolescence: implications for grades, depression, delinquency, and substance use. Developmental Psychology 2011;47(1):233–47.21244162
Licht AS, King BA, Travers MJ, Rivard C, Hyland AJ. Attitudes, experiences, and acceptance of smokefree policies among U.S. multiunit housing residents. American Journal of Public Health 2012;102(10):1868–71.22897557
Lin J, Zhu K, Soliván-Ortiz AM, Larsen SL, Schneid TR, Shriver CD, Lee S. Smokeless tobacco use and related factors: a study in the U.S. military population. American Journal of Health Behavior 2018;42(4):102–17.
Lindstrom M. Psychosocial work conditions, social capital, and daily smoking: a population based study. Tobacco Control 2004;13(3):289–95.15333886
Link BG, Phelan J. Social conditions as fundamental causes of disease. Journal of Health and Social Behavior 1995;Spec No:80–94.
Lipperman-Kreda S, Antin TMJ, Hunt GP. The role of multiple social identities in discrimination and perceived smoking-related stigma among sexual and gender minority current or former smokers. Drugs 2019;26(6):475–83.34262244
Lipperman-Kreda S, Paschall MJ, Grube JW. Perceived enforcement of school tobacco policy and adolescents’ cigarette smoking. Preventive Medicine 2009;48(6):562–6.19285525
Lippert AM, Corsi DJ, Venechuk GE. Schools influence adolescent e-cigarette use, but when? Examining the interdependent association between school context and teen vaping over time. Journal of Youth and Adolescence 2019;48(10):1899–911.31446585
Lisha NE, Sussman S. Relationship of high school and college sports participation with alcohol, tobacco, and illicit drug use: a review. Addictive Behaviors 2010;35(5):399–407.20100638
Loomis D, Richardson D. Race and the risk of fatal injury at work. American Journal of Public Health 1998;88(1):40.9584031
Lopez AD, Collishaw NE, Piha T. A descriptive model of the cigarette epidemic in developed countries. Tobacco Control 1994;3(3):242–47.
López G, Radford J. 2015, Foreign-born population in the United States statistical portrait: statistical portrait of the foreign-born population in the United States, 2015, May 3, 2017; <http://www.pewhispanic.org/2017/05/03/2015-statistical-information-on-immigrants-in-united-states/>; accessed: May 17, 2023.
Lorenzo-Blanco EI, Unger JB, Oshri A, Baezconde-Garbanati L, Soto D. Profiles of bullying victimization, discrimination, social support, and school safety: links with Latino/a youth acculturation, gender, depressive symptoms, and cigarette use. American Journal of Orthopsychiatry 2016;86(1):37–48.26752445
Mahabee-Gittens EM, Xiao Y, Gordon JS, Khoury JC. The role of family influences on adolescent smoking in different racial/ethnic groups. Nicotine & Tobacco Research 2012;14(3):264–73.22180584
Mai Y, Leonardo S, Soulakova JN. Smoke-free homes among single-parent families: differences associated with parental race/ethnicity and smoking behaviors. Preventive Medicine Reports 2018;9:18–23.29255668
Mai Y, Soulakova JN. Retrospective reports of former smokers: receiving doctor’s advice to quit smoking and using behavioral interventions for smoking cessation in the United States. Preventive Medicine Reports 2018;11:290–6.30116700
Malcarne VL, Chavira DA, Fernandez S, Liu PJ. The scale of ethnic experience: development and psychometric properties. Journal of Personality Assessment 2006;86(2):150–61.16599789
Marin G, Sabogal F, Marin BV, Otero-Sabogal R, PerezStable EJ. Development of a short acculturation scale for Hispanics. Hispanic Journal of Behavioral Sciences 1987;9(2):183–205.
Markham WA, Aveyard P. A new theory of health promoting schools based on human functioning, school organisation and pedagogic practice. Social Science & Medicine 2003;56(6):1209–20.12600359
Markkanen P, Quinn M, Galligan C, Chalupka S, Davis L, Laramie A. There’s no place like home: a qualitative study of the working conditions of home health care providers. Journal of Occupational and Environmental Medicine 2007;49(3):327–37.17351519
Markstrom CA, Li X, Blackshire SL, Wilfong JJ. Ego strength development of adolescents involved in adultsponsored structured activities. Journal of Youth and Adolescence 2005;34(2):85–95.
Marmot M, Bell R. Challenging health inequalities—implications for the workplace. Occupational Medicine (Oxford, England) 2010;60(3):162–4.20423942
Marynak K, Kenemer B, King BA, Tynan MA, MacNeil A, Reimels E. State laws regarding indoor public use, retail sales, and prices of electronic cigarettes—U.S. states, Guam, Puerto Rico, and U.S. Virgin Islands, September 30, 2017. Morbidity and Mortality Weekly Report 2017;66(49):1341–6.29240728
Marynak K, VanFrank B, Tetlow S, Mahoney M, Phillips E, Jamal Mbbs A, Schecter A, Tipperman D, Babb S. Tobacco cessation interventions and smokefree policies in mental health and substance abuse treatment facilities—United States, 2016. Morbidity and Mortality Weekly Report 2018;67(18):519–23.29746451
Mathur C, Stigler MH, Erickson DJ, Perry CL, Forster JL. Transitions in smoking behavior during emerging adulthood: a longitudinal analysis of the effect of home smoking bans. American Journal of Public Health 2014;104(4):715–20.24524528
McCabe SE, Hughes TL, Matthews AK, Lee JGL, West BT, Boyd CJ, Arslanian-Engoren C. Sexual orientation discrimination and tobacco use disparities in the United States. Nicotine & Tobacco Research 2019;21(4):523–31.29300994
McDonald EA, Ling PM. One of several “toys” for smoking: young adult experiences with electronic cigarettes in New York City. Tobacco Control 2015;24(6):588–93.25564287
McLeroy KR, Bibeau D, Steckler A, Glanz K. An ecological perspective on health promotion programs. Health Education Quarterly 1988;15(4):351–77.3068205
McMenamin SB, Yoeun SW, Halpin HA. Affordable Care Act impact on Medicaid coverage of smoking-cessation treatments. American Journal of Preventive Medicine 2018;54(4):479–85.29433953
Merrill RM, Thygerson AL. Religious preference, church activity, and physical exercise. Preventive Medicine 2001;33(1):38–45.11482994
Merzel CR, Isasi CR, Strizich G, Castaneda SF, Gellman M, Maisonet Giachello AL, Lee DJ, Penedo FJ, Perreira KM, Kaplan RC. Smoking cessation among U.S. Hispanic/Latino adults: findings from the Hispanic Community Health Study/Study of Latinos (HCHS/SOL). Preventive Medicine 2015;81:412–9.26515291
Mills AL, Messer K, Gilpin EA, Pierce JP. The effect of smoke-free homes on adult smoking behavior: a review. Nicotine & Tobacco Research 2009;11(10):1131–41.19633273
Mills SD, Fox RS, Gholizadeh S, Klonoff EZ, Malcarne VL. Acculturation and health behaviors among African Americans: a systematic review. Journal of Cross-Cultural Psychology 2017;48(7):1073–97.
Mills SD, Golden SD, O’Leary MC, Logan P, Hassmiller Lich K. Using systems science to advance health equity in tobacco control: a causal loop diagram of smoking. Tobacco Control 2023;32(3):287–95.34535509
Mishra GA, Pimple SA, Shastri SS. An overview of the tobacco problem in India. Indian Journal of Medical and Paediatric Oncology 2012;33(3):139–45.23248419
Moon-Howard J. African American women and smoking: starting later. American Journal of Public Health 2003;93(3):418–20.12604485
Mukherjea A, Modayil MV, Tong EK. Moving toward a true depiction of tobacco behavior among Asian Indians in California: prevalence and factors associated with cultural smokeless tobacco product use. Cancer 2018;124(Suppl 7):1607–13.29578599
Mukherjea A, Wackowski OA, Lee YO, Delnevo CD. Asian American, Native Hawaiian and Pacific Islander tobacco use patterns. American Journal of Health Behavior 2014;38(3):362–9.24636032
Murray LR. Sick and tired of being sick and tired: scientific evidence, methods, and research implications for racial and ethnic disparities in occupational health. American Journal of Public Health 2003;93(2):221–6.12554573
Nabe-Nielsen K, Quist HG, Garde AH, Aust B. Shiftwork and changes in health behaviors. Journal of Occupational and Environmental Medicine 2011;53(12):1413–7.22157647
Narain JP, Sinha DN. Tobacco epidemic in South-East Asia region: challenges and progress in its control. Indian Journal of Public Health 2011;55(3):151–4.22089681
National Academies of Sciences E, and Medicine. Promoting Positive Adolescent Health Behaviors and Outcomes: Thriving in the 21st Century. Washington (DC): The National Academies Press, 2020.
National Cancer Institute. Chapter 8: Occupation, the work environment and tobacco-related health disparities. In: A Socioecological Approach to Addressing Tobacco-Related Health Disparities. Tobacco Control Monograph 22. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2017a. NIH Publication No. 17-CA-8035A.
National Cancer Institute. A Socioecological Approach to Addressing Tobacco-Related Health Disparities. Tobacco Control Monograph 22. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2017b. NIH Publication No. 17-CA-8035A.
National Cancer Institute. Cancer Trends Progress Report, October 2022a; <https://progressreport.cancer.gov>; accessed: December 5, 2022.
National Cancer Institute. Clinicians’ advice to quit smoking (data up to date as of April 2022). In: Cancer Trends Progress Report, October 2022b; <https://progressreport.cancer.gov>; accessed: December 5, 2022.
National Cancer Institute, Centers for Disease Control and Prevention Smokeless Tobacco and Public Health: A Global Perspective. Bethesda, MD: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, and National Institutes of Health, National Cancer Institute, 2014.
National Cancer Institute and World Health Organization. The Economics of Tobacco and Tobacco Control. Tobacco Control Monograph 21. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute; and Geneva (Switzerland): World Health Organization, 2016. NIH Publication No. 16-CA-8029A.
National Institute for Occupational Safety and Health. Adverse Health Effects of Smoking and the Occupational Environment. Current Intelligence Bulletin 31, 1979; <https://www.cdc.gov/niosh/docs/79-122/default.html>; accessed: July 13, 2022.
Nelson DE, Emont SL, Brackbill RM, Cameron LL, Peddicord J, Fiore MC. Cigarette smoking prevalence by occupation in the United States. A comparison between 1978 to 1980 and 1987 to 1990. Journal of Occupational Medicine 1994;36(5):516–25.8027876
Nguyen KH, Gomez Y, Homa DM, King BA. Tobacco use, secondhand smoke, and smoke-free home rules in multiunit housing. American Journal of Preventive Medicine 2016;51(5):682–92.27423656
Nguyen KH, Subramanian SV, Sorensen G, Tsang K, Wright RJ. Influence of experiences of racial discrimination and ethnic identity on prenatal smoking among urban Black and Hispanic women. Journal of Epidemiology and Community Health 2012;66(4):315–21.20974840
Niaz K, Maqbool F, Khan F, Bahadar H, Ismail Hassan F, Abdollahi M. Smokeless tobacco (paan and gutkha) consumption, prevalence, and contribution to oral cancer. Epidemiology and Health 2017;39:e2017009.28292008
Nicksic NE, Harrell MB, Perez A, Pasch KE, Perry CL. School policy, administrator perceptions, and student e-cigarette use. Health Behavior and Policy Review 2018;5(4):72–82.30854404
Niedhammer I, Goldberg M, Leclerc A, David S, Bugel I, Landre MF. Psychosocial work environment and cardiovascular risk factors in an occupational cohort in France. Journal of Epidemiology and Community Health 1998;52(2):93–100.9578855
Nollen NL, Ahluwalia JS, Lei Y, Yu Q, Scheuermann TS, Mayo MS. Adult cigarette smokers at highest risk for concurrent alternative tobacco product use among a racially/ethnically and socioeconomically diverse sample. Nicotine & Tobacco Research 2016;18(4):386–94.25999383
Nowlin PR, Colder CR. The role of ethnicity and neighborhood poverty on the relationship between parenting and adolescent cigarette use. Nicotine & Tobacco Research 2007;9(5):545–56.17454711
O’Loughlin JL, Barry AD, O’Loughlin EK, Tremblay M. Home smoking bans may increase the risk of smoking onset in children when both parents smoke. Nicotine & Tobacco Research 2014;16(7):1009–13.24638854
Obasi EM, Leong FT. Construction and validation of the Measurement of Acculturation Strategies for People of African Descent (MASPAD). Cultural Diversity & Ethnic Minority Psychology 2010;16(4):526–39.21058816
Office of Disease Prevention and Health Promotion. Social determinants, n.d.; <https://wayback.archive-it.org/5774/20220413204846/https://www.healthypeople.gov/2020/leading-health-indicators/2020-lhi-topics/Social-Determinants>; accessed: April 30, 2020.
Okechukwu CA, Krieger N, Chen J, Sorensen G, Li Y, Barbeau EM. The association of workplace hazards and smoking in a U.S. multiethnic working-class population. Public Health Reports 2010;125(2):225–33.20297749
Olmsted KLR, Bray RM, Reyes-Guzman CM, Williams J, Kruger H. Overlap in use of different types of tobacco among active duty military personnel. Nicotine & Tobacco Research 2011;13(8):691–8.21498430
Ota A, Masue T, Yasuda N, Tsutsumi A, Mino Y, Ohara H, Ono Y. Psychosocial job characteristics and smoking cessation: a prospective cohort study using the Demand-Control-Support and Effort-Reward Imbalance job stress models. Nicotine & Tobacco Research 2010;12(3):287–93.20083647
Paek HJ, Hove T, Oh HJ. Multilevel analysis of the impact of school-level tobacco policies on adolescent smoking: the case of Michigan. Journal of School Health 2013;83(10):679–89.24020681
Pampel FC. Patterns of tobacco use in the early epidemic stages: Malawi and Zambia, 2000–2002. American Journal of Public Health 2005;95(6):1009–15.15914826
Park-Lee E, Ren C, Cooper M, Cornelius M, Jamal A, Cullen KA. Tobacco product use among middle and high school students—United States, 2022. Morbidity and Mortality Weekly Report 2022;71(45):1429–35.36355596
Park H, Cho SI, Lee C. Second hand smoke exposure in workplace by job status and occupations. Annals of Occupational and Environmental Medicine 2019;31:3.30719320
Parks MJ, Kingsbury JH, Boyle RG, Evered S. Household implementation of smoke-free rules in homes and cars: a focus on adolescent smoking behavior and secondhand smoke exposure. American Journal of Health Promotion 2019;33(1):70–8.29768925
Paschall MJ, Bersamin M. School-based mental health services, suicide risk and substance use among atrisk adolescents in Oregon. Preventive Medicine 2018;106:209–15.29126919
Pascoe EA, Smart Richman L. Perceived discrimination and health: a meta-analytic review. Psychological Bulletin 2009;135(4):531–54.19586161
Patel M, Mistry R, Maxwell AE, Divan HA, McCarthy WJ. Contextual factors related to conventional and traditional tobacco use among California Asian Indian immigrants. Journal of Community Health 2018;43(2):280–90.28852903
Peguero AA. Immigrant youth involvement in school-based extracurricular activities. The Journal of Educational Research 2011;104(1):19–27.
Perikleous EP, Steiropoulos P, Paraskakis E, Constantinidis TC, Nena E. E-cigarette use among adolescents: an overview of the literature and future perspectives. Frontiers in Public Health 2018;6:86.29632856
Pesko MF, Bains J, Maclean C, Cook BL. Nearly half of small employers using tobacco surcharges do not provide tobacco cessation wellness programs. Health Affairs 2018;37(3):473–81.29505370
Pfeffer J. Dying for a Paycheck: How Modern Management Harms Employee Health and Company Performance—and What We Can Do About It. New York (NY): HarperCollins Publishers, 2018.
Phelan JC, Link BG. Is racism a fundamental cause of inequalities in health? Annual Review of Sociology 2015;41:311–30.
Phelan JC, Link BG, Tehranifar P. Social conditions as fundamental causes of health inequalities: theory, evidence, and policy implications. Journal of Health and Social Behavior 2010;51(Suppl):S28–S40.20943581
Price JH, Yingling F, Dake JA, Telljohann SK. Adolescent smoking cessation services of school-based health centers. Health Education & Behavior 2003;30(2):196–208.12693523
Prochaska JJ, Das S, Young-Wolff KC. Smoking, mental illness, and public health. Annual Review of Public Health 2017;38:165–85.
Punnett L, Cherniack M, Henning R, Morse T, Faghri P. A conceptual framework for integrating workplace health promotion and occupational ergonomics programs. Public Health Reports 2009;124(Suppl 1):S16–S25.
Purnell JQ, Peppone LJ, Alcaraz K, McQueen A, Guido JJ, Carroll JK, Shacham E, Morrow GR. Perceived discrimination, psychological distress, and current smoking status: results from the Behavioral Risk Factor Surveillance System Reactions to Race module, 2004–2008. American Journal of Public Health 2012;102(5):844–51.22420821
Quist HG, Christensen U, Carneiro IG, Hansen JV, Bjorner JB. Do colleagues influence our lifestyle: the matter of smoking, body mass index and leisure-time physical activity? Preventive Medicine 2014;67:166–70.25073076
Ramchand R, Ialongo NS, Chilcoat HD. The effect of working for pay on adolescent tobacco use. American Journal of Public Health 2007;97(11):2056–62.17901448
Reda AA, Kaper J, Fikrelter H, Severens JL, van Schayck CP. Healthcare financing systems for increasing the use of tobacco dependence treatment. Cochrane Database of Systematic Reviews 2009, Issue 2. Art. No.: CD004305. DOI: 10.1002/14651858.CD004305.pub3.
Reiss K, Lehnhardt J, Razum O. Factors associated with smoking in immigrants from non-western to western countries—what role does acculturation play? A systematic review. Tobacco Induced Diseases 2015;13(1):11.25908932
Rhew IC, David Hawkins J, Oesterle S. Drug use and risk among youth in different rural contexts. Health & Place 2011;17(3):775–83.21414831
Robalino JD, Macy M. Peer effects on adolescent smoking: Are popular teens more influential? PLoS One 2018;13(7):e0189360.30001357
Robinson WL, Harper GW, Schoeny ME. Reducing substance use among African American adolescents: effectiveness of school-based health centers. Clinical Psychology: Science and Practice 2003;10(4):491–504.33414577
Rodriquez EJ, Fernandez A, Livaudais-Toman JC, Perez-Stable EJ. How does acculturation influence smoking behavior among Latinos? The role of education and national background. Ethnicity & Disease 2019;29(2):227–38.31057307
Rogers CJ, Forster M, Unger JB. Ethnic variations in the relationship between multiple stress domains and use of several types of tobacco/nicotine products among a diverse sample of adults. Addictive Behaviors Reports 2018;7:96–102.29892703
Rose A, Fagan P, Lawrence D, Hart A, Jr., Shavers VL, Gibson JT. The role of worksite and home smoking bans in smoking cessation among U.S. employed adult female smokers. American Journal of Health Promotion 2011;26(1):26–36.21879940
Rowe DJ, Dunn JR, Muntaner C. The impact of job strain on smoking cessation and relapse in the Canadian population: a cohort study. Journal of Epidemiol Community Health 2015a;69(10):931–6.
Rowe DJ, Dunn JR, Muntaner C. The impact of job strain on smoking cessation and relapse in the Canadian population: a cohort study. Journal of Epidemiology and Community Health 2015b;69(10):931–6.25903755
Russell ST, Seif H, Truong NL. School outcomes of sexual minority youth in the United States: evidence from a national study. Journal of Adolescence 2001;24(1):111–27.11259074
Russo ET, Hulse TE, Adamkiewicz G, Levy DE, Bethune L, Kane J, Reid M, Shah SN. Comparison of indoor air quality in smoke-permitted and smoke-free multiunit housing: findings from the Boston Housing Authority. Nicotine & Tobacco Research 2015;17(3):316–22.25156526
Rutter M. Fifteen Thousand Hours: Secondary Schools and Their Effects on Children. Cambridge (MA): Harvard University Press, 1982.
Ryabov I. Relation of peer effects and school climate to substance use among Asian American adolescents. Journal of Adolescence 2015;42:115–27.25996088
Sanderson Cox LS, Okuyemi K, Choi WS, Ahluwalia JS. A review of tobacco use treatments in U.S. ethnic minority populations. American Journal of Health Promotion 2011;25(5 Suppl):S11–S30.21510783
Sanderson DM, Ekholm O, Hundrup YA, Rasmussen NK. Influence of lifestyle, health, and work environment on smoking cessation among Danish nurses followed over 6 years. Preventive Medicine 2005;41(3–4):757–60.16081152
Santhosh L, Meriwether M, Saucedo C, Reyes R, Cheng C, Clark B, Tipperman D, Schroeder SA. From the sidelines to the frontline: how the Substance Abuse and Mental Health Services Administration embraced smoking cessation. American Journal of Public Health 2014;104(5):796–802.24625143
Schantz AD, Bruk-Lee V. Workplace social stressors, drugalcohol-tobacco use, and coping strategies. Journal of Workplace Behavioral Health 2016;31:222–41.
Schillo BA, Cuccia AF, Patel M, Simard B, Donovan EM, Hair EC, Vallone D. JUUL in school: teacher and administrator awareness and policies of e-cigarettes and JUUL in U.S. middle and high schools. Health Promotion Practice 2020;21(1):20–4.31530185
Schnall P, Dobson M, Rosskam E. Unhealthy Work: Causes, Consequences, Cures. In: Elling RH, editor. Critical Approaches in the Health Social Sciences Series. Amityville (NY): Baywood Publishing, 2009:411.
Schreuders M, Nuyts PAW, van den Putte B, Kunst AE. Understanding the impact of school tobacco policies on adolescent smoking behaviour: a realist review. Social Science & Medicine 2017;183:19–27.28458071
Schroeder SA, Morris CD. Confronting a neglected epidemic: tobacco cessation for persons with mental illnesses and substance abuse problems. Annual Review of Public Health 2010;31:297–314.
Schwartz SJ, Unger JB, Zamboanga BL, Szapocznik J. Rethinking the concept of acculturation: implications for theory and research. American Psychologist 2010;65(4):237–51.20455618
Seelig AD, Rivera AC, Powell TM, Williams EC, Peterson AV, Littman AJ, Maynard C, Street AE, Bricker JB, Boyko EJ. Patterns of smoking and unhealthy alcohol use following sexual trauma among U.S. service members. Journal of Traumatic Stress 2017;30(5):502–11.28906037
Seo DC, Huang Y. Systematic review of social network analysis in adolescent cigarette smoking behavior. Journal of School Health 2012;82(1):21–7.22142171
Shackleton N, Jamal F, Viner R, Dickson K, Hinds K, Patton G, Bonell C. Systematic review of reviews of observational studies of school-level effects on sexual health, violence and substance use. Health & Place 2016;39:168–76.27126364
Shiffman S, Brockwell SE, Pillitteri JL, Gitchell JG. Use of smoking-cessation treatments in the United States. American Journal of Preventive Medicine 2008;34(2):102–11.18201639
Simons-Morton BG, Farhat T. Recent findings on peer group influences on adolescent smoking. Journal of Primary Prevention 2010;31(4):191–208.20614184
Singh PN, Yel D, Sin S, Khieng S, Lopez J, Job J, Ferry L, Knutsen S. Tobacco use among adults in Cambodia: evidence for a tobacco epidemic among women. Bulletin of the World Health Organization 2009;87(12):905–12.20454481
Siru R, Hulse GK, Tait RJ. Assessing motivation to quit smoking in people with mental illness: a review. Addiction 2009;104(5):719–33.19413788
Smith EA, Malone RE. Tobacco promotion to military personnel: “the plums are here to be plucked”. Military Medicine 2009;174(8):797–806.19743733
Smucker S, Meadows SO, Beckman R. Use of electronic cigarettes and other tobacco products among active component services members. Military Medicine 2021:usab252.
Snowden LR, Hines AM. A scale to assess African American acculturation. Journal of Black Psychology 1999;25(1):36–47.
Snyder K, Vick JH, King BA. Smoke-free multiunit housing: a review of the scientific literature. Tobacco Control 2016;25(1):9–20.25566811
Sodowsky GR, Lai EWM, Plake B. Moderating effects of sociocultural variables on acculturation attitudes of Hispanics and Asian Americans. Journal of Counseling and Development 1991;70(1):194–204.
Sommers BD, Gunja MZ, Finegold K, Musco T. Changes in self-reported insurance coverage, access to care, and health under the Affordable Care Act. JAMA: the Journal of the American Medical Association 2015;314(4):366–74.26219054
Sorensen G, Barbeau E. Steps to a healthier U.S. work-force: integrating occupational health and safety and worksite health promotion: state of the science 2012. In: Research Compendium—The NIOSH Total Worker Health Program: Seminal Research Papers. Washington (DC): U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health, May, 2012:1–65.
Sorensen G, Barbeau E, Hunt MK, Emmons K. Reducing social disparities in tobacco use: a social contextual model for reducing tobacco use among bluecollar workers. American Journal of Public Health 2004;94(2):230–9.14759932
Sorensen G, McLellan DL, Sabbath EL, Dennerlein JD, Nagler EM, Hurtado DA, Pronk NP, Wagner GR. Integrating worksite health protection and health promotion: a conceptual model for intervention and research. Preventive Medicine 2016;91:188–96.27527576
Sorensen G, Quintiliani L, Pereira L, Yang M, Stoddard A. Work experiences and tobacco use: findings from the gear up for health study. Journal of Occupational and Environmental Medicine 2009;51(1):87–94.19136877
Sorensen G, Stoddard A, Hammond SK, Hebert JR, Avrunin JS, Ockene JK. Double jeopardy: workplace hazards and behavioral risks for craftspersons and laborers. American Journal of Health Promotion 1996;10(5):355–63.10163305
Sorensen G, Stoddard A, LaMontagne A, Emmons K, Hunt M, Youngstrom R, McLellan D, Christiani D. A comprehensive worksite cancer prevention intervention: behavior change results from a randomized controlled trial in manufacturing worksites (United States). Cancer Causes and Control 2002;13(6):493–502.12195637
Stanton CA, Highland KB, Tercyak KP, Luta G, Niaura RS. Authoritative parenting and cigarette smoking among multiethnic preadolescents: the mediating role of anti-tobacco parenting strategies. Journal of Pediatric Psychology 2014;39(1):109–19.24306966
Steege AL, Baron SL, Marsh SM, Menendez CC, Myers JR. Examining occupational health and safety disparities using national data: a cause for continuing concern. American Journal of Industrial Medicine 2014;57(5):527–38.24436156
Stein A, Suttie J, Baker L, Agans R, Xue W, Bowling JM. Predictors of smoke-free policies in affordable multiunit housing, North Carolina, 2013. Preventing Chronic Disease 2015;12:E73.25974143
Stephany TM. Health hazard concerns of home care nurses. A staff nurse perspective. Journal of Nursing Administration 1993;23(12):12–3.
Stephenson M. Development and validation of the Stephenson Multigroup Acculturation Scale (SMAS). Psychological Assessment 2000;12(1):77–88.10752366
Sterling TD, Weinkam JJ. Smoking characteristics by type of employment. Journal of Occupational Medicine 1976;18(11):743–54.993866
Sternthal MJ, Slopen N, Williams DR. Racial disparities in health: how much does stress really matter? Du Bois Review: Social Science Research on Race 2011;8(1):95–113.29887911
Stewart EB. Individual and school structural effects on African American high school students’ academic achievement. The High School Journal 2007;91(2):16–34.
Stone AL, Elbers-Carlisle SK. Workplace racial discrimination, negative emotions based on treatment due to race, and substance use. Substance Use & Misuse 2020;55(12):1925–34.32669029
Stone S, Han M. Perceived school environments, perceived discrimination, and school performance among children of Mexican immigrants. Children and Youth Services Review 2005;27(1):51–66.
Suris JC, Berchtold A, Akre C. Reasons to use e-cigarettes and associations with other substances among adolescents in Switzerland. Drug and Alcohol Dependence 2015;153:140–4.26077606
Swanberg JE, Pitt-Catsouphes M, Drescher-Burke K. A question of justice: disparities in employees’ access to flexible schedule arrangements. Journal of Family Issues 2005;26(6):866.
Syamlal G, Jamal A, King BA, Mazurek JM. Electronic cigarette use among working adults—United States, 2014. Morbidity and Mortality Weekly Report 2016;65(22):557–61.27281058
Syamlal G, King BA, Mazurek JM. Workplace smoke-free policies and cessation programs among U.S. working adults. American Journal of Preventive Medicine 2019;56(4):548–62.30772152
Tan ASL, Young-Wolff KC, Carter-Harris L, Salloum RG, Banerjee SC. Disparities in the receipt of tobacco treatment counseling within the U.S. context of the Affordable Care Act and meaningful use implementation. Nicotine & Tobacco Research 2018;20(12):1474–80.29059372
Tate C. Cigarette Wars: The Triumph of “The Little White Slaver”. New York (NY): Oxford University Press, 1999.
Thompson AR, Gregory A. Examining the influence of perceived discrimination during African American adolescents’ early years of high school. Education and Urban Society 2011;43(1):3–25.
Thun M, Peto R, Boreham J, Lopez AD. Stages of the cigarette epidemic on entering its second century. Tobacco Control 2012;21(2):96–101.22345230
Tong EK, Nguyen TT, Vittinghoff E, Pérez-Stable EJ. Smoking behaviors among immigrant Asian Americans: rules for smoke-free homes. American Journal of Preventive Medicine 2008;35(1):64–7.18541178
Tong EK, Tang H, Chen MS Jr, McPhee SJ. Provider smoking cessation advice among California AsianAmerican smokers. American Journal of Health Promotion 2011;25(5 Suppl):S70–S74.21510790
Tran AG, Lee RM, Burgess DJ. Perceived discrimination and substance use in Hispanic/Latino, African-born Black, and Southeast Asian immigrants. Cultural Diversity & Ethnic Minority Psychology 2010;16(2):226–36.20438161
Trinidad DR, Gilpin EA, Lee L, Pierce JP. Do the majority of Asian-American and African-American smokers start as adults? American Journal of Preventive Medicine 2004;26(2):156–8.14751329
Trinidad DR, Pérez-Stable EJ, White MM, Emery SL, Messer K. A nationwide analysis of U.S. racial/ethnic disparities in smoking behaviors, smoking cessation, and cessation-related factors. American Journal of Public Health 2011;101(4):699–706.21330593
Tsai J, Homa DM, Gentzke AS, Mahoney M, Sharapova SR, Sosnoff CS, Caron KT, Wang L, Melstrom PC, Trivers KF. Exposure to secondhand smoke among nonsmokers—United States, 1988–2014. Morbidity and Mortality Weekly Report 2018;67(48):1342–6.30521502
Tsai J, Homa DM, Neff LJ, Sosnoff CS, Wang L, Blount BC, Melstrom PC, King BA. Trends in secondhand smoke exposure, 2011–2018: impact and implications of expanding serum cotinine range. American Journal of Preventive Medicine 2021;61(3):e109–e117.34419235
Tucker JS, Shadel WG, Golinelli D, Ewing B. Alternative tobacco product use and smoking cessation among homeless youth in Los Angeles County. Nicotine & Tobacco Research 2014;16(11):1522–6.25145375
U.S. Bureau of Labor Statistics. Labor Force Characteristics by Race and Ethnicity, 2016, 2017; <https://www.bls.gov/opub/reports/race-and-ethnicity/2016/pdf/home.pdf>; accessed: April 29, 2020.
U.S. Bureau of Labor Statistics. Food and beverage serving and related workers, 2019; <https://www.bls.gov/ooh/food-preparation-and-serving/food-and-beverage-serving-and-related-workers.htm>; accessed: April 29, 2020.
U.S. Department of Health and Human Services. The Health Consequences of Smoking: Cancer and Chronic Lung Disease in the Workplace. A Report of the Surgeon General. Rockville (MD): U.S. Department of Health and Human Services, Public Health Service, Office on Smoking and Health, 1985. DHHS Publication No. (PHS) 85-50207.
U.S. Department of Health and Human Services. Tobacco Use Among U.S. Racial/Ethnic Minority Groups-African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1998.
U.S. Department of Health and Human Services. The Health Consequences of Involuntary Exposure to Tobacco Smoke: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, Coordinating Center for Health Promotion, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2006.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2012.
U.S. Department of Health and Human Services. The Health Consequences of Smoking—50 Years of Progress: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2014.
U.S. Department of Health and Human Services. E-Cigarette Use Among Youth and Young Adults. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2016.
U.S. Department of Health and Human Services. Smoking Cessation. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2020.
U.S. Department of Labor. Silica, crystalline: health effects, n.d.; <https://www.osha.gov/silica-crystalline/health-effects#healthinfo>; accessed: December 5, 2022.
U.S. Preventive Services Task Force. Final recommendation statement—tobacco use in children and adolescents: primary care interventions, April 2020; <https://www.uspreventiveservicestaskforce.org/uspstf/recommendation/tobacco-and-nicotine-use-prevention-in-children-and-adolescents-primary-care-interventions>; accessed: March 6, 2023.
Unger JB. Preventing substance use and misuse among racial and ethnic minority adolescents: why are we not addressing discrimination in prevention programs? Substance Use & Misuse 2015;50(8–9):952–5.26361900
Unger JB. Perceived discrimination as a risk factor for use of emerging tobacco products: more similarities than differences across demographic groups and attributions for discrimination. Substance Use & Misuse 2018;53(10):1638–44.29338581
Unger JB, Urman R, Cruz TB, Majmundar A, Barrington-Trimis J, Pentz MA, McConnell R. Talking about tobacco on Twitter is associated with tobacco product use. Preventive Medicine 2018;114:54–6.29898418
Unnever JD, Cullen FT, Barnes JC. Racial discrimination, weakened school bonds, and problematic behaviors. Journal of Research in Crime and Delinquency 2015;53(2):139–64.
Valencia CV, Dove M, Tong EK. Factors associated with receipt of smoking cessation advice and assistance by health professionals among Latino and non-Latino White smokers with Medicaid insurance in California. JAMA Network Open 2022;5(1):e2144207.35044467
Valente TW, Fujimoto K, Soto D, Ritt-Olson A, Unger JB. A comparison of peer influence measures as predictors of smoking among predominately Hispanic/Latino high school adolescents. Journal of Adolescent Health 2013;52(3):358–64.
van den Brand FA, Nagelhout GE, Reda AA, Winkens B, Evers S, Kotz D, van Schayck OC. Healthcare financing systems for increasing the use of tobacco dependence treatment. Cochrane Database of Systematic Reviews 2017, Issue 9. Art. No.: CD004305. DOI: 10.1002/14651858.CD004305.pub5.
van Loon AJ, Tijhuis M, Surtees PG, Ormel J. Lifestyle risk factors for cancer: the relationship with psychosocial work environment. International Journal of Epidemiology 2000;29(5):785–92.11034957
Vandewater EA, Park SE, Carey FR, Wilkinson AV. Intergenerational transfer of smoking across three generations and forty-five years. Nicotine & Tobacco Research 2014;16(1):11–7.23943844
Vidrine JI, Rabius V, Alford MH, Li Y, Wetter DW. Enhancing dissemination of smoking cessation quitlines through T2 translational research: a unique partnership to address disparities in the delivery of effective cessation treatment. Journal of Public Health Management and Practice 2010;16(4):304–8.20520368
Vijayaraghavan M, Benmarnhia T, Pierce JP, White MM, Kempster J, Shi Y, Trinidad DR, Messer K. Income disparities in smoking cessation and the diffusion of smokefree homes among U.S. smokers: results from two longitudinal surveys. PLoS One 2018;13(7):e0201467.30052671
Vijayaraghavan M, Messer K, White MM, Pierce JP. The effectiveness of cigarette price and smoke-free homes on low-income smokers in the United States. American Journal of Public Health 2013;103(12):2276–83.24134354
Vuolo M, Staff J. Parent and child cigarette use: a longitudinal, multigenerational study. Pediatrics 2013;132(3):e568–e577.23918887
Wallace JM, Jr., Vaughn MG, Bachman JG, O’Malley PM, Johnston LD, Schulenberg JE. Race/ethnicity, socioeconomic factors, and smoking among early adolescent girls in the United States. Drug and Alcohol Dependence 2009;104(Suppl 1):S42–S49.19628345
Walton K, Gentzke AS, Murphy-Hoefer R, Kenemer B, Neff LJ. Exposure to secondhand smoke in homes and vehicles among U.S. youths, United States, 2011–2019. Preventing Chronic Disease 2020;17:E103.32915130
Ward JB, Gartner DR, Keyes KM, Fliss MD, McClure ES, Robinson WR. How do we assess a racial disparity in health? Distribution, interaction, and interpretation in epidemiological studies. Annals of Epidemiology 2019;29:1–7.30342887
Ward KD, Eissenberg T, Rastam S, Asfar T, Mzayek F, Fouad MF, Hammal F, Mock J, Maziak W. The tobacco epidemic in Syria. Tobacco Control 2006;15(Suppl 1) i24–i29.16723671
Webb Hooper M, Baker EA, de Ybarra DR, McNutt M, Ahluwalia JS. Acculturation predicts 7-day smoking cessation among treatment-seeking African-Americans in a group intervention. Annals of Behavioral Medicine 2012;43(1):74–83.21909848
Webb Hooper M, Calixte-Civil P, Verzijl C, Brandon KO, Asfar T, Koru-Sengul T, Antoni MH, Lee DJ, Simmons VN, Brandon TH. Associations between perceived racial discrimination and tobacco cessation among diverse treatment seekers. Ethnicity & Disease 2020;30(3):411–20.32742143
Webb Hooper M, Carpenter K, Payne M, Resnicow K. Effects of a culturally specific tobacco cessation intervention among African American Quitline enrollees: a randomized controlled trial. BMC Public Health 2018;18(1):123.29321008
Weiss JW, Garbanati JA. Effects of acculturation and social norms on adolescent smoking among Asian-American subgroups. Journal of Ethnicity in Substance Abuse 2006;5(2):75–90.
Wellman RJ, Dugas EN, Dutczak H, O’Loughlin EK, Datta GD, Lauzon B, O’Loughlin J. Predictors of the onset of cigarette smoking: a systematic review of longitudinal population-based studies in youth. American Journal of Preventive Medicine 2016;51(5):767–78.27180028
Whitsel LP, Benowitz N, Bhatnagar A, Bullen C, Goldstein F, Matthias-Gray L, Grossmeier J, Harris J, Isaac F, Loeppke R, . Guidance to employers on integrating e-cigarettes/electronic nicotine delivery systems into tobacco worksite policy. Journal of Occupational and Environmental Medicine 2015;57(3):334–43.25742539
Wiehe SE, Aalsma MC, Liu GC, Fortenberry JD. Gender differences in the association between perceived discrimination and adolescent smoking. American Journal of Public Health 2010;100(3):510–6.20075313
Wilkins NJ, Krause KH, Verlenden JV, Szucs LE, Ussery EN, Allen CT, Stinson J, Michael SL, Ethier KA. School connectedness and risk behaviors and experiences among high school students—Youth Risk Behavior Survey, United States, 2021. Morbidity and Mortality Weekly Report Supplements 2023;72(1):13–21.37104377
Williams DR, Lawrence JA, Davis BA. Racism and health: evidence and needed research. Annual Review of Public Health 2019;40(1):105–25.
Williams DR, Yan Y, Jackson JS, Anderson NB. Racial differences in physical and mental health: socio-economic status, stress and discrimination. Journal of Health Psychology 1997;2(3):335–51.22013026
Wills TA. Stress and coping in early adolescence: relationships to substance use in urban school samples. Health Psychology 1986;5(6):503–29.3492372
Wills TA, Bantum EOC, Pokhrel P, Maddock JE, Ainette MG, Morehouse E, Fenster B. A dual-process model of early substance use: tests in two diverse populations of adolescents. Health Psychology 2013;32(5):533.23646836
Wilson KM, Klein JD, Blumkin AK, Gottlieb M, Winickoff JP. Tobacco-smoke exposure in children who live in multiunit housing. Pediatrics 2011;127(1):85–92.21149434
Wilson KM, Torok M, McMillen R, Tanski S, Klein JD, Winickoff JP. Tobacco smoke incursions in multiunit housing. American Journal of Public Health 2014;104(8):1445–53.24922124
Wilson KM, Torok MR, McMillen RC, Klein JD, Levy DE, Winickoff JP. Tobacco-smoke incursions and satisfaction among residents with children in multiunit housing, United States, 2013. Public Health Reports 2017;132(6):637–45.28977766
Wong MD, Coller KM, Dudovitz RN, Kennedy DP, Buddin R, Shapiro MF, Kataoka SH, Brown AF, Tseng CH, Bergman P, . Successful schools and risky behaviors among low-income adolescents. Pediatrics 2014;134(2):e389–e396.25049339
Yang J, Anyon Y. Race and risk behaviors: The mediating role of school bonding. Children and Youth Services Review 2016;69:39–48.
Yong LC, Luckhaupt SE, Li J, Calvert GM. Quit interest, quit attempt and recent cigarette smoking cessation in the U.S. working population, 2010. Occupational and Environmental Medicine 2014;71(6):405–14.24497440
Zhang J, Wang Z. Factors associated with smoking in Asian American adults: a systematic review. Nicotine & Tobacco Research 2008;10(5):791–801.18569752
Zhang L, Finan LJ, Bersamin M, Fisher DA, Paschall MJ. Sexual orientation-based alcohol, tobacco, and other drug use disparities: the protective role of school-based health centers. Youth & Society 2020;52(7):1153–73.34321700
Zhang X, Martinez-Donate A, Rhoads N. Parental practices and attitudes related to smoke-free rules in homes, cars, and outdoor playgrounds in U.S. households with underage children and smokers, 2010–2011. Preventing Chronic Disease 2015;12:E96.26086609
Zhang X, Martinez-Donate AP, Kuo D, Piper M. Beyond cigarette smoking: smoke-free home rules and use of alternative tobacco products. Perspectives in Public Health 2016;136(1):30–3.26275410
Zhang X, Pu J. E-cigarette use among U.S. adolescents: secondhand smoke at home matters. International Journal of Public Health 2016;61(2):209–13.26781545
Zhen-Duan J, Taylor MJ. The use of an ecodevelopmental approach to examining substance use among rural and urban Latino/a youth: peer, parental, and school influences. Journal of Ethnicity in Substance Abuse 2014;13(2):104–25.24853361

## Chapter 4 Appendix

### Appendix 4.1 Search Terms Used for Chapter 4

Table 4A.1 Search terms used for Chapter 4

Topic | Search terms
Social influence
Social influence (all topics) (Indexes: PubMed, ABI Inform, EBSCO, PsycINFO, and Web of Science) | (“social influences” OR sociocultural OR “socio-cultural” OR “social network” OR “social networks” OR “social support” OR “social supports” OR family influence* OR peer influence* OR racism OR discrimination OR accultura* OR “ethnic identity” OR “ethnic identities” OR trauma OR violence OR “adverse childhood” OR ses OR socioeconomic OR “socio-economic” OR poverty OR financial stress* OR unemploy* OR homeless* OR stigma OR stigmas OR stigmatiz* OR medicaid OR urban* OR rural OR “inner city” OR “inner cities” OR suburban OR “blue collar”); AND; (tobacco OR smok* OR nicotine OR blunt* OR vap* OR “electronic cigarette” OR “e-cigarette” OR “electronic nicotine delivery system” OR hookah OR shisha OR waterpipe OR “water pipe” OR narghile OR cigar* OR snus OR “smokeless tobacco” OR “chewing tobacco” OR bidi OR menthol); AND; (minority OR minorities OR disparity OR disparities OR LGB* OR transgender OR transgender* OR “sexual minority” OR “sexual minorities” OR “African American” OR “African Americans” OR africanamerican* OR American Indian* OR Native American* OR Alaska Villager* OR Alaskan Villager* OR Alaska Native* OR Alaskan Native* OR Pacific Islander* OR “First Nations” OR “First Nation” OR Maori OR Inuit OR Hispanic OR Hispanic* OR Latin* OR Mexican* OR central american* OR latin american* OR Asian OR Asians OR Chinese OR vietnamese OR korean OR koreans OR filipino* OR hawaiian OR hawaiian* OR salvadoran* OR Puerto Rican* OR cuban OR cubans OR honduran* OR multicultural OR “multi-cultural” OR multiracial OR “multi-racial” OR multiethnic OR “multi-ethnic” OR incarcerated OR disabled OR schizophrenic OR “mental health” OR “mentally ill” OR “mental illness” OR blind OR deaf); Filters activated: Publication date from 2008/01/01, English
Environmental influence
Housing environment (Index: PubMed) | “smokefree homes” OR “multi-unit housing”; OR; “smoke-free homes,” AND/OR “household smoking bans,” AND/OR “home smoking bans,” AND/OR “home smoking restrictions,” AND/OR “household smoking restrictions”; AND; (minority OR minorities OR disparity OR disparities OR LGB* OR transgender OR transgender* OR “sexual minority” OR “sexual minorities” OR “African American” OR “African Americans” OR africanamerican* OR American Indian* OR Native American* OR Alaska Villager* OR Alaskan Villager* OR Alaska Native* OR Alaskan Native* OR Pacific Islander* OR “First Nations” OR “First Nation” OR Maori OR Inuit OR Hispanic OR Hispanic* OR Latin* OR Mexican* OR central american* OR latin american* OR Asian OR Asians OR Chinese OR vietnamese OR korean OR koreans OR filipino* OR hawaiian OR hawaiian* OR salvadoran* OR Puerto Rican* OR cuban OR cubans OR honduran* OR multicultural OR “multi-cultural” OR multiracial OR “multi-racial” OR multiethnic OR “multi-ethnic” OR incarcerated OR disabled OR schizophrenic OR “mental health” OR “mentally ill” OR “mental illness” OR blind OR deaf) OR (“LGBTQ”) OR (“gender and sexual minority”)
School environment (Indexes: PubMed, PsycINFO, and ERIC) | Search #1:; (“minority” OR “African-American”) OR (“Black”) OR (“Hispanic”) OR (“Latino”) OR (“LGBTQ”) OR (“gender and sexual minority”); AND; (“school environment”); AND; (“tobacco” OR “smoking”); Search #2:; (“school”); AND; (“policies,” OR “tobacco,” OR “smoking,” OR “vaping,” OR “e-cigarette,” OR “Juul”)
Work environment (Index: PubMed) | Search #1:; ((worker*[tiab] OR “work environment” [tiab] OR occupation*[tiab] OR business*[tiab] OR workplace*[tiab] OR job*[tiab] OR work*[tiab]); OR; (“job strain”[tiab] OR “psychosocial work environment”[tiab] OR “workplace violence” [tiab] OR “work-family conflict”[tiab] OR “work hours”[tiab] OR “work schedule”* [tiab] OR “workplace abuse”*[tiab] OR “workplace discrimination”[tiab] OR “sexual harassment”[tiab] OR “occupational hazard”*[tiab])); AND; (smoking[tiab] OR tobacco[tiab] OR “electronic cigarette”*[tiab] OR e-cigarette*[tiab] OR ecigarette*[tiab] OR “electronic nicotine delivery system”*[tiab] OR “electronic nicotine system”* [tiab] OR snuff[tiab] OR “smokeless tobacco”*[tiab] OR smoker*[tiab] OR “smoking initiation”[tiab] OR “tobacco initiation”[tiab] OR “smoking cessation”[tiab] OR “tobacco cessation”[tiab] OR “smoking relapse”[tiab] OR “tobacco relapse”[tiab]); (AND; (race[tiab] OR ethnicity[tiab] OR LGBT[tiab] OR lesbian[tiab] OR gay[tiab] OR transgender[tiab] OR bisexual[tiab] OR gender[tiab])); Search #2 (including MESH terms):; ((worker*[tiab] OR occupation*[tiab] OR business*[tiab] OR workplace*[tiab] OR job[tiab] OR job site*[tiab] OR jobsite*[tiab] OR work[tiab] OR worksite*[tiab] OR work site*[tiab] OR Work[mh] OR Occupational Groups[mh] OR Workplace[mh] OR Occupations[mh] OR Occupational Medicine[mh] OR Occupational Health[mh] OR Occupational Health Services[mh])); OR; ((job strain[tiab] OR work environment*[tiab] OR psychosocial workplace*[tiab] OR social workplace*[tiab] OR workplace violence[tiab] OR occupational violence[tiab] OR work-family conflict*[tiab] OR work hours[tiab] OR work schedule*[tiab] OR shift work[tiab] OR night shift*[tiab] OR workplace abuse[tiab] OR abuse at work[tiab] OR work break[tiab] OR work breaks[tiab] OR workplace discrimination[tiab] OR discrimination at work[tiab] OR sexual harassment[tiab] OR work harassment[tiab] OR workplace harassment[tiab] OR occupational hazard*[tiab] OR work hazard*[tiab] OR workplace hazard*[tiab] OR occupational health hazard*[tiab] OR workplace health hazard*[tiab] OR occupational safety[tiab] OR workplace safety[tiab] OR work safety[tiab] OR workplace crime*[tiab] OR crime at work[tiab] OR violence at work[tiab] OR accidents at work[tiab] OR occupational accident*[tiab] OR work accident*[tiab] OR workplace accident*[tiab] OR workplace crowding[tiab] OR workplace stress[tiab] OR workplace stressor*[tiab] OR stress at work[tiab] OR occupational stress[tiab] OR occupational stressor*[tiab] OR work stress[tiab] OR work stressor*[tiab] OR workplace strain[tiab] OR occupational strain[tiab] OR strain at work[tiab] OR worksite wellness[tiab] OR work-site wellness[tiab] OR workplace wellness[tiab] OR worksite resource*[tiab] OR workplace resource*[tiab] OR occupational resource*[tiab] OR workplace policy[tiab] OR workplace policies[tiab] OR occupational noise[tiab] OR workplace noise[tiab] OR Workplace Violence[mh] OR Work-Life Balance[mh] OR Work Schedule Tolerance[mh] OR Shift Work Schedule[mh] OR Prejudice[mh] OR Social Discrimination[mh] OR Sexual Harassment[mh] OR Harassment, Non-Sexual[mh] OR Occupational Health[mh] OR Occupational Health Services[mh] OR Occupational Medicine[mh] OR Accidents, Occupational[mh] OR Occupational Injuries[mh] OR Asthma, Occupational[mh] OR Occupational Exposure[mh] OR Occupational Diseases[mh] OR Air Pollutants, Occupational[mh] OR Occupational Stress[mh] OR Noise, Occupational[mh])); AND; (tobacco[tiab] OR smok*[tiab] OR nicotine[tiab] OR blunt*[tiab] OR vap*[tiab] OR electronic cigarette*[tiab] OR e-cigarette*[tiab] OR ecigarette*[tiab] OR electronic nicotine delivery system*[tiab] OR vaping product*[tiab] OR hookah*[tiab] OR shisha[tiab] OR waterpipe*[tiab] OR water pipe*[tiab] OR narghile*[tiab] OR cigar*[tiab] OR snus[tiab] OR snuff[tiab] OR smokeless tobacco*[tiab] OR chewing tobacco*[tiab] OR bidi[tiab] OR bidis[tiab] OR smoking initiation[tiab] OR tobacco initiation[tiab] OR smoking cessation*[tiab] OR tobacco cessation*[tiab] OR smoking relapse*[tiab] OR tobacco relapse*[tiab] OR quit attempt*[tiab] OR Nicotine[mh] OR Tobacco[mh] OR Tobacco Use[mh] OR Tobacco Smoking[mh] OR Tobacco Products[mh] OR Smoking[mh] OR Smokers[mh] OR Tobacco Use Disorder[mh] OR Tobacco Smoke Pollution[mh] OR Smoking Devices[mh] OR Smoking Water Pipes[mh] OR Electronic Nicotine Delivery Systems[mh] OR Vaping[mh] OR Smoking Reduction[mh] OR Smoking Cessation[mh] OR Tobacco Use Cessation[mh] OR Smoking Cessation Agents[mh] OR Tobacco Use Cessation Devices[mh] OR Smoking Prevention[mh] OR Ex-Smokers[mh] OR Smoke-Free Policy[mh]); Search # 3 (based on terms found in initial searches):; (secondhand smoke at work[tiab] OR environmental smoke at work[tiab] OR workplace secondhand smoke[tiab] OR workplace environmental smoke[tiab] OR smokefree worksite*[tiab] OR smoke-free worksite*[tiab] OR smokefree workplace*[tiab] OR smoke-free workplace*[tiab] OR tobacco-free worksite*[tiab] OR tobacco-free workplace*[tiab])
Healthcare environment (Indexes: PubMed and PsycINFO) | “tobacco” and “treatment access”; “discrimination” and “healthcare” and “tobacco”; “tobacco” and “insurance” and “access”; “tobacco use” and “race” and “treatment”; “tobacco” and “primary care”; “tobacco” and “mental health treatment”; “tobacco” and “substance abuse treatment”; Timespan: 2008–2020

1 Cotinine is a metabolite of nicotine that is widely used to measure exposure to tobacco smoke. The established range definition for exposure to secondhand smoke is 0.05–10 nanograms/milliliter.