# Chapter 3 Physiological, Chemosensory, and Genetic Influences of Menthol and Other Flavors in Tobacco Products

## Introduction

All currently marketed tobacco products contain natural or synthetic flavor chemicals and other additives, compounds, constituents, and ingredients that elicit multisensory experiences. These multisensory experiences include taste (gustation), smell (olfaction), trigeminal senses (cooling, burning, throat or mouth irritation), touch, sight, and sound. These may include, for example, the audial and visual cues offered by the colors and sounds of cigar wrappers, or the smell of a cigarillo, such as Swisher Sweets “Purple Swish” brand, which can emit a sweet grape odor even when sealed in its purple wrapper.

Tobacco processing includes a set of steps that contributes to the overall multisensory experience. Tobacco processing carefully considers the type of tobacco (e.g., Turkish blend); the blending of tobacco plants into a tobacco product; growing conditions; the fermentation and aging processes that make tobacco and tobacco smoke sweet, bitter, spicy, or smooth; and flavor additives (Box 3.1). Premium cigars can vary in taste and smell, even if flavors are not added to the cigars. Each tobacco product elicits a multisensory experience that has the potential to increase the appeal of, experimentation with, continued use of, and dependence on tobacco products.

Box 3.1 Cigarette Processing Steps

- Remove stems and store tobacco;
- Condition tobacco and prepare flue-cured blend, burley blend, and Turkish blend;
- Add casing materials (sugar, licorice, cocoa, etc.) to the burley blend;
- Prepare final blend by combining flue-cured, burley, and Turkish blends;
- Cut tobacco into cigarette-type filler;
- Apply top dressing (e.g., spices, sweeteners, etc.); and
- Make and pack cigarettes (R.J. Reynolds 1976).

Multisensory experiences, including the experience of flavors, can contribute to tobacco-related disparities. For example, menthol cigarettes and flavored little cigars and cigarillos are disproportionately used by particular groups characterized by race and ethnicity, sexual orientation and gender identity, and age (see Chapter 2, Table 2.6). Although African American people comprised about 12% of the U.S. population during 1980 (11.7%) and 2020 (12.4%) (Gibson and Jung 2002; Jones et al. 2021), an estimated 40% of excess deaths due to menthol cigarette smoking in the United States between 1980 and 2018 occurred among African Americans (Mendez and Le 2021). Intentionally designed and flavored tobacco products that deliver multisensory experiences, combined with decades of targeted marketing to certain minoritized racial and ethnic groups, sexual orientation and gender identity groups, age groups, and lower socioeconomic status (SES) groups, contribute to disparities across the tobacco use continuum.

What is flavor? Flavor includes the entirety of sensations perceived when one eats food, drinks a beverage, or consumes a tobacco product. Flavor is a combination of taste, smell, and the physical sensations one feels in the mouth, such as hot, cold, tingling, crispness, fluidity, or oiliness. Flavor perception is a synthesis of orthonasal and retronasal olfactory sensations and taste, with the latter including the ability to experience sweet, salty, sour, bitter, and umami (savory) tastes (Wolfe et al. 2014). Physical sensations in the mouth also contribute to flavor perceptions and are mediated by the sense of touch, including the ability to sense cold, hot, and tingling. In essence, flavorants are chemicals that can be added or created through chemical processes and differentially activate taste, smell, and physical sensations, contributing to flavor experiences. The term tastant refers to a substance that elicits taste, which is one aspect of multisensory flavor experiences. However, flavorants can also elicit sensory experiences, such as cooling, without the experiences of taste and smell.

Flavor researchers have recognized that defining flavor as odor and taste only is too narrow (Berenstein 2017). As one organizer of the first scientific symposium on flavors, hosted by the American Chemical Society in 1937, explained, “other factors than taste and smell contribute directly to flavor. Menthol, for instance, produces a strong feeling of coolness in mouth and nose, and this coolness is a particularly important part of the flavor of peppermint” (Crocker 1937, p. 273). Accordingly, oral somatosensation is also a key modality of flavor (Small 2012), and additives that provide oral somatosensation are flavoring chemicals.

The genetics, physiology, and chemosensory aspects of taste, smell, and somatosensory stimuli are the basis for the detection of flavor chemicals and for multisensory experiences. Both the olfaction and gustatory systems interact with somatosensation, such as temperature and touch, so that people who smoke experience the cooling and burning sensations of flavor chemicals, such as menthol. Not all people who smoke like the experience of menthol in cigarettes (Oncken et al. 2015; Risso et al. 2016a, 2017). Whether a particular flavor experience or sensation appeals to someone is influenced by multilevel factors, including genetic and physiological variables (Drewnowski 1997), as well as targeted marketing to specific groups discussed in Chapter 5.

Flavor chemicals and additives that elicit multisensory experiences in tobacco products are a multibillion-dollar industry. International Flavors & Fragrances, Inc. (IFF), a major supplier to the tobacco industry, reported revenues totaling more than $12 billion in the fiscal year ending in December 2022, with a 5-year annual revenue growth rate of nearly 30% (IFF n.d.). As described later in this chapter, the tobacco industry and its flavor manufacturers have spent considerable time over the years conducting experiments to determine the combinations of flavors and other chemical additives that elicit multisensory effects and provide appealing sensory experiences.

Evidence in tobacco industry documents indicates that flavored products have been specifically marketed to young people, women, and members of certain racial and ethnic groups (Gardiner 2004; Carpenter et al. 2005). For example, the 1984 Brown & Williamson Taste Segmentation Study showed that people 35 years of age and younger who smoked preferred fruity flavors more so than older populations (Brown & Williamson 1984; Gardiner 2004; Carpenter et al. 2005). Additionally in 1991, Lorillard tobacco company stated that, “Given young adults (sic) proclivity toward flavors in other categories (i.e., soft drinks, wine coolers), a flavor enhanced menthol product may appeal to these smokers” (Lorillard 1991). R.J. Reynolds examined the aspects of taste that appealed to young adults, including not having a dry or lasting aftertaste, having a pleasant aroma, and leaving a pleasant and fresh taste (Philip Morris Records Collection 2010). The same document listed “key smoker wants” among “younger adult Black smokers,” including “Lot of Menthol,” “Leaves Fresh Taste,” and “Not Bitter” (Philip Morris Records Collection 2010, p. 22). Based on its market research of menthol products from competitors (e.g., Newport), R.J. Reynolds recommended concepts for exploration including the development of a menthol aftertaste and aroma that would appeal to Black male and female 18- to 24-year-olds who smoked Newport cigarettes. Proposed strategies to improve R.J. Reynolds’ products included adding polymer pellets and aroma precursors (Philip Morris Records Collection 2010). These same tobacco industry documents indicated the tobacco industry’s desire to reach young adult Black people, referred to throughout this reference as “Black Menthol” through urban markets and the military.

The tobacco industry has conducted its own genetic, chemosensory, and taste preferences research. For example:

- In 2002, R.J. Reynolds proposed a study to ascertain if it was possible to differentiate between people who smoke, do not smoke, or use heated tobacco products based on their gene expression profiles (Hellman and Guy 2002).
- R.J. Reynolds conducted chemosensory research to understand how additives like cocoa and sugar could improve the quality of the smoking experience for consumers (R.J. Reynolds 1987).
- British American Tobacco Company studied how to reduce irritation from smoking by adding sweeteners at different points in tobacco paper processing (British American Tobacco Company 1968).

Additionally, the industry has long acknowledged that the sensory properties of menthol are central to its role in increasing the appeal of smoking. In discussion groups conducted for British American Tobacco conducted among people who smoked menthol and “potential users,” the Creative Research Group concluded that mentholated cigarettes “undeniably impart a cooling influence, and … a by-product of this is to reduce harshness and to modify or mask the tobacco taste” (Creative Research Group 1982, p. 20; Yerger 2011). Philip Morris explored the appeal of menthol cigarettes in interviews with 1,367 people who smoked. Findings from its 1979 report of taste preferences indicated that:

“What menthol smokers report they like and other smokers report they don’t like about menthols is largely in terms of effect rather than taste. The key effects that seem to appeal to menthol smokers are menthol’s perceived

– Cooling effects
– Clean, antiseptic effects
– Slightly numbing, anesthetic effects
– Heady, lifting effects” (The Roper Organization Inc. 1979, p. 5–6).

These are just a few examples of how the tobacco industry has used flavor chemicals and additives in the design and engineering of its products to appeal to specific groups of consumers. Compared with the tobacco industry’s decades of research on the physiological and chemosensory effects of flavors in tobacco products on consumers, these topics have been explored less in public health research. The industry’s knowledge of chemosensory and physiological effects of flavors on specific populations, as revealed in tobacco industry documents (Philip Morris Records Collection 2010), helped inform targeted product development and marketing.

This chapter specifically discusses individual-level factors (chemical senses, physiology, and human genetics) that influence the use of tobacco products containing natural and synthetic flavor chemicals, menthol, and other chemical additives that contribute to multisensory flavor experiences. It also discusses the flavor chemicals used in tobacco products, including the sensory effects, physiological effects, and somatosensory perceptions experienced by people who use them. Additionally, this chapter discusses how tobacco product flavors might help to explain some tobacco-related health disparities.

### A Note on Race and Genetic Variation

As discussed in Chapter 1, race is a social construct that has been used to “identify, distinguish and marginalize some groups” and is best understood as a form of stratification rather than a distinct group of genetic dispositions (National Human Genome Research Institute 2023). It is important to recognize that there is greater genetic variance within than between racial and ethnic population groups (Jorde and Wooding 2004; Mersha and Beck 2020). This chapter explores why people in some socially stratified population groups (e.g., by race, gender, age) and those who carry specific genes may be more likely to use menthol or nonmenthol cigarettes. The emerging science on the role of genes in flavor experiences should be understood from a multidisciplinary perspective and in context with the multilevel factors influencing tobacco-related health disparities across the lifespan and across the tobacco use continuum (National Cancer Institute [NCI] 2017, Figure 1.1, p. 8). These multilevel factors include tobacco industry targeted marketing, tobacco product engineering tactics, differential pricing and marketing of flavored tobacco products in specific neighborhoods, structural and systemic racism and discrimination, policies, interpersonal relationships, stress, and societal and cultural influences. Other chapters in this report discuss how these additional factors interact across the lifespan to influence tobacco-related health disparities.

## Literature Review Methods

A literature search of PubMed, Google, U.S. Food and Drug Administration (FDA) Tobacco Products web portal, and Truth Tobacco Industry Documents (formerly known as Legacy Tobacco Documents Library) was conducted for studies in English that were published through May 11, 2022. Search terms are listed in Table 3.1.

Table 3.1 Search strategies used for this chapter

Topic | Search strategy
Genetic, physiological, and chemosensory influences of flavors and menthol in the use of tobacco products | Time period: Through May 2022; Indexes: PubMed, Google Scholar, FDA Tobacco Products web portal, and Truth Tobacco Industry Documents; Language: English; Search terms: Flavors, menthol, transient receptor potential ion channels, synthetic cooling agents, synthetic sweeteners, Generally Recognized as Safe, GRAS, Flavor and Extract manufacturers Association, FEMA, flavor additives, sweet/candy/fruit flavors, flavored tobacco product categories, cigarettes, cigars, cigarillos, little cigars, smokeless tobacco, electronic cigarettes, e-cigarettes, various flavor chemicals and classes of flavors used in tobacco products, disparities in flavored tobacco products use, physiology of flavor perception, somatosensory perception of flavors, nicotinic receptors, sensory irritant receptors, sensory receptors, TRPM8/TRPA1/TRPV1 and flavor perception, mechanisms of flavor sensing, genetic basis of disparities in flavor preferences, and combinations thereof

Notes: Because this chapter focuses on various basic physiological, molecular, and genetic mechanisms of flavor sensing, several of the cited studies pertain to global populations and studies, not just to studies of U.S. populations and those based in the United States. Content focusing on tobacco-related health disparities and the genetic basis of flavor sensing is derived primarily from studies of nationally representative datasets of U.S. populations.

Information was summarized from the sources retrieved through the search, including research manuscripts; review articles; internal documents from tobacco manufacturers; and rules, regulations, and guidance documents for tobacco products from FDA. As this chapter focuses on various and basic physiological, molecular, and genetic mechanisms of flavor sensing, several of the cited studies pertain to U.S. populations and U.S.-based studies, as well as global populations and studies. Content focusing on tobacco use disparities and the genetic basis of flavor sensing is primarily derived from studies using national data comprised of representative samples of U.S. populations.

## History of Flavor Chemicals in Tobacco Products

Flavor chemicals are used in tobacco products to elicit flavor sensations that can mask unpleasant tastes or odors and enhance taste (Carpenter et al. 2005). The history of flavors provides context to facilitate understanding of their use in tobacco products. For example, spices, a particular class of flavors, have been used for thousands of years to give flavor to foods and to cover up the pungent taste of meat prior to refrigeration (Rowe 2005). One of the oldest written formulas for flavors involved the use of myrrh, cinnamon, calamus, and cassia in olive oil, which was described in the book of Exodus of the Bible (Sell 2014). Until the discovery of distillation with ethanol, olive oil was an important solvent that was used to extract various flavorants (Sell 2014).

During medieval times, techniques were developed to extract flavorants from spices and essential oils through distillation. People who were wealthy used these flavor extracts as fragrances to improve the smell of the human body. Many of these spices and oils were transported from East Asia and the Middle East into Europe, even during the Dark Ages. The migration of flavors and fragrances, despite disapproval of their use by some churches, could not be halted as trade across the world expanded along with advancements in chemistry. While distillation revolutionized the fragrance and flavor industries, advances in synthetic and analytic organic chemistry in the nineteenth and twentieth centuries turned flavor chemistry into a more precise science (Sell 2014).

In the Industrial Age, chemists advanced the capacity to isolate and create chemicals in the laboratory that can be produced on a large scale for commercialization. For example, in 1834, cinnamaldehyde became one of the first chemicals to be isolated and then later synthesized (in 1852) by the Roure Bertrand Company (Rowe 2005). In the late 1800s, other chemicals, many of which are used today in tobacco products—such as benzaldehyde, methyl salicylate, vanillin, coumarin, cinnamic acid, saccharin, and lactic acid—became some of the first to be isolated or synthesized. The advancement of various analytic techniques (e.g., gas chromatography or mass spectrometry) allowed for the synthesis of flavor chemicals in the laboratory and resulted in mass commercialization of flavor chemicals (Rowe 2005).

After the Roure Bertrand Company isolated cinnamaldehyde, several other companies began to introduce more flavors and fragrances for use in a variety of consumer products. Table 3.2 lists some of the leading companies that manufacture flavors and fragrances. These companies produce chemicals that function to provide a product with a specified taste or smell (Rowe 2005). Many of these companies are large and multinational, and several of them produce flavor chemicals, such as menthol, that are commonly used by tobacco companies. The mass production of a wide variety of flavors and fragrances for a variety of consumer products has allowed the tobacco industry to produce products that contain multiple flavors and fragrances, which provide diverse sensory experiences. Chemosensory experiences produced by flavor chemicals are discussed later in this chapter.

Table 3.2 Leading companies that manufacture flavors and fragrance

Company | Primary products
International Flavors and Fragrances (IFF) | Produces essential oils for smoking tobacco and coolants
Symrise (entity formed by the merger of Haarmann & Reimer with Dragoco) | Vanillin, menthol, and filter capsules
Givaudan | Produces flavors for tobacco companies (Givaudan n.d.)
Firmenich | Produces flavors for the tobacco industry
Quest International | Cooling agents
Takasago | Menthol, vanillin, and cooling agents
Kerry | Food groups
Danisco | Food groups
Nestle | Food groups
Procter & Gamble | Household and consumer goods
Unilever | Household and consumer goods
L’Oréal | Household and consumer goods
Frutarom (acquired by IFF) | Aroma chemicals, domestic fragrances, and savory flavors
Duckworth’s | Aroma chemicals, domestic fragrances, and savory flavors
Flavor & Fragrance Specialties | Aroma chemicals, domestic fragrances, and savory flavors
Sensient Technologies | Food and beverage colors, aroma chemicals, flavors in foods, other ingredients, cosmetics, pharmaceuticals, and household products
Robertet Groupe | Fragrances, flavors, and essential oils, including tobacco, for use in perfumes, cosmetics, aromatherapy, and food
T. Hasegawa | Flavors, including tobacco flavors and e-cigarette liquids
Huaboa International and Guangdong Golden Leaf; Technology Development Co., Ltd., a subsidiary of Huaboa | Fragrances and flavors, including tobacco flavors, lining paper and filter, filter stick materials, and filter stick equipment
Mane | Flavors and fragrances in foods and perfumes

Source: Rowe (2005), with updates.

## Past Regulation of Flavor Chemicals in Food and Tobacco Products

In 2009, through the Family Smoking Prevention and Tobacco Control Act (Tobacco Control Act) (Public Law 111-31), Congress gave FDA regulatory authority over tobacco products, including their manufacturing, sale, and distribution with an amendment to the Federal Food, Drug, and Cosmetic Act (FD&C Act) of 1938 (FDA 2020b). This authority also included the authority to adopt tobacco product standards that, among other things, may regulate the construction, components, ingredients, additives, constituents, and properties of the tobacco product (FDA 2020b). The Tobacco Control Act followed more than a century of federal regulation over flavor additives in food, drugs, and cosmetic products.

### Flavors Used in Foods

Growing concerns about hidden dangers in the nation’s food supply contributed to the enactment of the Pure Food and Drugs Act of 1906. One principal concern was that advances in chemistry made it possible for unscrupulous manufacturers to use synthetic preservatives, flavorings, and other additives to disguise and pass off lowquality and inferior foods as “authentic” (Berenstein 2017). Subsequently, the FD&C Act of 1938 authorized FDA to regulate food and drug safety (FDA 2018b). The FD&C Act was amended by the Food Additives Amendment of 1958, introducing a process for companies to submit food additive petitions to FDA for substances added to food (FDA 2018b). This amendment specified that if FDA deemed no harm would be caused by the additive in the limits of its intended use, then FDA would define these limits in its regulatory decision.

The 1958 Food Additives Amendment of the FD&C Act also specified that substances added to food do not have to undergo such FDA review if they are “generally recognized as safe” (GRAS), among qualified experts, under the conditions of their intended use (FDA 2018b). Under this provision, the FD&C Act implicitly authorized industry (i.e., commercial actors involved in food preparation) to conclude that substances added to or articles used as components in food, drinks, or chewing gum meet the criteria for GRAS. However, FDA may determine that such a conclusion has no basis and that the use of a substance in food requires approval as a food additive. FDA has also published a partial list of substances that are GRAS for use in food (FDA 2023; Code of Federal Regulations 2023 [Title 21, Parts 182 and 184]). Flavoring substances that are regulated as food additives are listed in FDA’s regulations in Title 21, Code of Federal Regulations Part 172, and GRAS flavors are listed in FDA’s regulations in Title 21, Code of Federal Regulations Parts 182 and 184 (Code of Federal Regulations 2023). Importantly, neither authorization as a food additive nor a conclusion of GRAS status—both of which are limited to food—applies to the use of these substances in tobacco products of any type.

A global network of industry organizations evaluates or compiles evaluations of the safety of flavors in foods—as well as fragrances in other products, such as cosmetics, detergents, and other consumer products—in response to national and international regulations. These industry-based organizations vary depending on whether the chemical is used as a flavor or a fragrance (Table 3.3). The U.S.-based Flavor and Extract Manufacturers Association (FEMA) maintains a list of more than 2,800 flavors that it considers to be GRAS for use in food, and the list is updated biannually (FEMA n.d.a).

Table 3.3 Industry organizations for fragrances and for flavors used in food

Organization | Focus
Geneva | Fragrances
| Fragrances
Geneva | Flavors in foods and beverages
(FEMA) | Flavors in foods for human consumption

Source: Rowe (2005), with updates.

### Food Additive Approvals or GRAS Conclusions Apply to Foods, Not to Inhaled or Combusted Tobacco Products

Many electronic cigarette (e-cigarette) vendors have advertised that the chemicals used to manufacture e-cigarette liquids (e-liquids) are GRAS, per FEMA specifications, to wrongly imply their safety for inhalation (U.S. Department of Health and Human Services [USDHHS] 2016). However, no regulatory body has approved the safe level of any chemicals, including flavors, in tobacco products. As mentioned previously, GRAS conclusions are applicable only to ingestion of foods and are not applicable to the inhalation of tobacco products, combustible tobacco products, or combusted or aerosolized chemicals. In its 2018 Advanced Notice of Proposed Rulemaking (ANPRM) titled “Regulation of Flavors in Tobacco Products,” FDA noted that,

Certain substances may be authorized as a food additive or may be considered “generally recognized as safe” (GRAS) for certain uses in food. However, being authorized as a food additive or being considered GRAS, in and of itself, does not mean that the substances are safe when used in a tobacco product. The food additive approval or GRAS status of a substance applies only to specific intended uses in food, and are not supported by studies that account for inhalation toxicity (Federal Register 2018, p. 12298).

The ANPRM (2018, p. 12298) went on to explicitly discuss metabolic differences between inhaled and oral routes of exposure:

Importantly, exposure to chemicals via the inhalation route can have very different effects from oral exposure, and most tobacco products are inhaled (Federal Register 2018, citing Klaassen 2013). For example, direct “portal of entry” effects to the respiratory tract, which is relatively more sensitive than the gastrointestinal tract, can occur upon inhalation exposure. There are also important metabolic differences between the two routes of exposure: After oral ingestion, a substance can be detoxified through “first-pass metabolism” in the liver before reaching systemic circulation. By contrast, substances introduced into the body via inhalation go directly into systemic circulation without the same potential for detoxification (Federal Register 2018, citing Klaassen 2013).

In sum, compared to ingestion, inhalation results in higher absorption of toxicants (Jabba et al. 2022; Leventhal et al. 2022). FDA has, however, acknowledged that GRAS status is not dispositive but may be informative when evaluating the toxicity of ingesting chemicals added to oral tobacco products, such as smokeless tobacco (FDA 2020c; Federal Register 2021).

In various announcements, FEMA (2015, 2016, 2020) has stated emphatically that the GRAS designation applies only to food and cannot be applied to flavorants in e-cigarettes. FEMA also declared that occupational exposure limits (OELs) (established for some flavorants by the Occupational Safety and Health Administration), recommended exposure limits (RELs) (established by the National Institute for Occupational Safety and Health), and threshold limit values (TLVs) (established by the American Conference of Government Industrial Hygienists) are (a) intended to serve as regulatory limits (for OELs) or benchmarks for limiting exposure to substances in the workplace (RELs and TLVs) and (b) should not be used as safety thresholds for e-cigarette use. For example, FEMA noted that OELs have been established for some flavor chemicals, but these limits “have no relevance to exposure to flavors from the use of e-cigarettes” (FEMA 2015, p. 2).

## Disparities in Flavored Tobacco Product Use

As noted earlier in this chapter, the tobacco and flavor industries are multibillion-dollar industries that distribute their products worldwide (IFF n.d.). Flavors play a critical role in the appeal of tobacco products for youth, women, and certain minoritized racial and ethnic and sexual orientation and gender identity groups. Further, specific flavors and flavored products are target marketed to some groups who disproportionately use them (see Chapter 5). For example, approximately 80% of youth who begin using any tobacco product start with one that is flavored (USDHHS 2016). In one study, an estimated 40% of adolescents across five states who began smoking cigarettes used menthol cigarettes (Nonnemaker et al. 2013). Additionally, using data from the Population Assessment of Tobacco and Health (PATH) Study, more than 50% of young people 24 years of age and younger who ever used a filtered cigar or cigarillo reported that the first cigar product they smoked was flavored (Rostron et al. 2020). A systematic review by Smith and colleagues (2017) found that women who smoke are more likely than men to use mentholated cigarettes. Using data from the 2009 to 2010 National Adult Tobacco Survey, menthol cigarette use was higher among lesbian, gay, bisexual, and transgender (LGBT) groups than it was among people who identify as heterosexual or straight (Fallin et al. 2015). Hinds 3rd and colleagues (2018), using data from the Marketing and Promotions Across Colleges in Texas project, found that African American, Hispanic, and Asian young adults (18–29 years of age) are more likely than White young adults to use flavored cigars. Studies have shown that 70–90% of African American people who smoke use menthol cigarettes (Gardiner 2004; Pletcher et al. 2006; Lawrence et al. 2010; Caraballo and Asman 2011; Jones et al. 2013). Further, data from the 2017–2019 National Survey on Drug Use and Health showed that the overall prevalence of menthol cigarette use was 88.1% among Black people who smoked (Chapter 2; Table 2.6). The menthol compound is discussed in greater detail later in this chapter.

Flavors in e-cigarettes have been a key driver of the rise in the use of tobacco products by youth (King 2020, 2022). The 2016 Surgeon General’s report on E-Cigarette Use Among Youth and Young Adults concluded that the rising use of e-cigarettes among youth constitutes a serious health problem that is driven by the availability of youth-appealing flavors, with both youth and young adults citing flavors as a primary reason for using these products (USDHHS 2016). Thousands of differently flavored e-cigarettes have been marketed to consumers (Zhu et al. 2014; Krüsemann et al. 2019; Havermans et al. 2021) with flavors created to produce multisensory experiences in those who are susceptible to tobacco use, nicotine dependence, and tobacco-related illnesses. Using data from the 2016–2017 PATH Study, Rostron and colleagues (2020) found that more than 80% of young people 24 years of age and younger who ever used e-cigarettes reported that their first e-cigarette was flavored. According to data from the 2021 National Youth Tobacco Survey (NYTS), about 85% of middle and high school students who used e-cigarettes used a flavored e-cigarette (Park-Lee et al. 2021).

## Regulation of Flavors in Tobacco Products

Attention in the public health community to flavor chemicals in tobacco products has grown during the past decade, in part because the Tobacco Control Act (2009) gives FDA the authority to regulate additives, constituents, and ingredients in tobacco products. This authority includes the ability to regulate parts and components of tobacco products (e.g., wrapping paper, filters, liquids, tips, devices, and software). The Tobacco Control Act prohibits the sale of cigarettes with “characterizing flavors,” with the exception of menthol and tobacco flavors (Figure 3.1). The Tobacco Control Act authorizes FDA to regulate cigarettes, cigarette tobacco, smokeless tobacco, and “roll your own” tobacco. FDA issued a final rule (the “deeming rule”) in May 2016 extending the Act’s applicability to all products meeting the definition, at that time,^1^ of a “tobacco product”—under the Food, Drug, and Cosmetic Act—including cigars, hookahs, e-cigarette products, and components and parts but excluding accessories of tobacco products. Therefore, all newly deemed tobacco products must use one of three pathways to be approved for marketing: (1) submit a Premarket Tobacco Product Application, (2) undergo review for substantial equivalence, or (3) obtain an exemption for substantial equivalence (Federal Register 2016). FDA reviews Premarket Tobacco Product Applications to determine whether marketing of the product(s) is appropriate for the protection of the public health. FDA has the authority to issue a marketing authorization order under any of these pathways, which allows the product to be legally sold in the United States. E-cigarette products that have been granted marketing authorization as of 2023 include classic and rich tobacco-flavored NJOY, original flavored Vuse, and tobacco-flavored Logic (FDA n.d.).

Because of the dramatic increase in the use of e-cigarettes, especially flavored e-cigarettes, among youth, in January 2020, FDA issued a statement of enforcement priorities against certain unauthorized flavored e-cigarette products that appeal to youth. Specifically, companies that did not stop manufacturing, distributing, and selling cartridge- or pod-based e-cigarettes (except for menthol and tobacco flavors) risked enforcement actions by FDA (2020a). Importantly, the guidance preserved FDA’s ability to shift its enforcement priorities, including in response to changes in patterns of product use among youth.

Figure 3.1 Excerpt from the Family Smoking Prevention and Tobacco Control Act

Section 907 Tobacco Product Standards

“(A) Special Rule for Cigarettes. Beginning 3 months after the date of enactment of the Family Smoking Prevention and Tobacco Control Act, a cigarette or any of its component parts (including the tobacco, filter, or paper) shall not contain, as a constituent (including a smoke constituent) or additive, an artificial or natural flavor (other than tobacco or menthol) or an herb or spice, including strawberry, grape, orange, clove, cinnamon, pineapple, vanilla, coconut, licorice, cocoa, chocolate, cherry, or coffee, that is a characterizing flavor of the tobacco product or tobacco smoke. Nothing in this subparagraph shall be construed to limit the Secretary’s authority to take action under this section or other sections of this Act applicable to menthol or any artificial or natural flavor, herb, or spice not specified in this subparagraph.”

Source: Family Smoking Prevention and Tobacco Control Act

In 2021, FDA indicated that it intended to propose two product standards that prohibit (1) menthol as a characterizing flavor in cigarettes and (2) all characterizing flavors other than tobacco, including menthol, in cigars (FDA 2021). On April 22, 2022 (published in the Federal Register on May 4, 2022), FDA issued its proposed product standards. The proposed tobacco product standard for menthol cigarettes would prohibit menthol as a characterizing flavor in cigarettes and cigarette components or parts, including those sold separately to consumers (Federal Register 2022a). The proposed tobacco product standard prohibiting characterizing flavors other than tobacco in cigars “would provide that a cigar or any of its components or parts (including the tobacco, filter, or wrapper, as applicable) must not contain, as a constituent (including a smoke constituent) or additive, an artificial or natural flavor (other than tobacco) or an herb or spice, including, but not limited to, strawberry, grape, orange, clove, cinnamon, pineapple, vanilla, coconut, licorice, cocoa, chocolate, cherry, coffee, mint, or menthol, that is a characterizing flavor of the tobacco product or tobacco smoke” (Federal Register 2022b, p. 26397).

Both proposed rules outline factors that, if finalized, would be relevant when determining whether a product has a characterizing flavor:

- The presence and amount of artificial or natural flavor additives, compounds, constituents, or ingredients, or any other flavoring ingredient in a tobacco product, including its components or parts;
- The multisensory experience (i.e., taste, aroma, and cooling or burning sensations in the mouth and throat) of a flavor during use of a tobacco product, including its components or parts;
- Flavor representations (including descriptors), either explicit or implicit, in or on the labeling (including packaging) or advertising of tobacco products; and
- Any other means that impart flavor or represent that the tobacco product has a characterizing flavor.

FDA has proposed that both tobacco product standards would be effective 1 year after the date of the publication of the final rule. If finalized as proposed, the rules would prohibit the manufacture, distribution, sale, or offering for distribution or sale, in the United States, of a cigarette or cigar or any of its components or parts that do not comply with Title 21 Code of Federal Regulations Parts 1162 (cigarettes) and 1166 (cigars) after such effective date. Importantly, as stated in the proposed rules, these proposed product standards do not include a prohibition on individual consumer possession or use, and FDA cannot and will not enforce against individual consumers for possession or use of menthol cigarettes or flavored cigars.

Some states and many localities have used the term flavored tobacco product to refer to products that impart a taste or smell other than the taste or smell of tobacco (Public Health Law Center 2023b). Explicitly incorporating the multisensory aspects of flavor such as cooling into flavor definitions could enhance the comprehensiveness of flavored tobacco product restrictions. The Public Health Law Center (2023a), a nongovernment organization, has revised its recommended definition of flavored tobacco products to more explicitly include sensory aspects (Box 3.2).

Thus, understanding flavor chemicals and their multisensory effects—whether synthetic or natural—has important implications for the regulation of tobacco products.

Box 3.2 Public Health Law Center (2023a) definition of flavored tobacco products

“FLAVORED TOBACCO PRODUCT” means any tobacco product that imparts:

1. a taste or odor distinguishable by an ordinary consumer, other than the taste or odor of tobacco, either prior to or during the consumption of such tobacco product, including but not limited to tastes or odors relating to any fruit, chocolate, vanilla, honey, candy, cocoa, dessert, alcoholic beverage, mint, wintergreen, menthol, herb, or spice; or
2. a cooling or numbing sensation distinguishable by an ordinary consumer during the consumption of such tobacco product.

PRESUMPTIVE FLAVORED TOBACCO PRODUCT. Any communication by or on behalf of the manufacturer or retailer of a tobacco product that such tobacco product imparts a taste or odor other than the taste or odor of tobacco, or that imparts a cooling or numbing sensation, constitutes presumptive evidence that the tobacco product is a flavored tobacco product.

This includes but is not limited to public statements that a product has a minty or cooling effect, such as describing the product as “chill,” “ice,” “fresh,” “arctic,” or “frost.”

## Flavor Chemicals and Other Chemicals in Tobacco Products

Flavor chemicals in tobacco products can mask the bitter taste, irritation, pain, and harsh sensations of tobacco and nicotine and, thus, make tobacco easier to use (Cummings et al. 2002; Galeotti et al. 2002; Carpenter et al. 2005; Harris 2006). Flavor chemicals, such as menthol, elicit sensory perceptions, a reinforcing factor that can influence the uptake of tobacco products among youth and young adults, increase the risk of nicotine dependence, impede quitting tobacco use, and increase the abuse liability of tobacco products (i.e., the potential of a drug product or substance to result in intentional, nontherapeutic use, even once, to achieve a desired psychological or physiological effect) (Center for Drug Evaluation and Research 2017; Wong et al. 2020; Bono et al. 2022; Center for Tobacco Products 2022). Additionally, flavor chemicals other than menthol can also increase the abuse liability of tobacco products, including e-cigarettes and cigars (Wong et al. 2020; Bono et al. 2022).

The following section discusses functional chemicals, which are designed to influence flavor perception, meaning that they stimulate the receptors in the oropharyngeal cavity, a topic discussed later in this chapter. Such chemicals stimulate the senses, including through aroma; physical sensations (such as tingling, cooling, warming, or astringency); and sweet, bitter, sour, salty, or umami (savory) tastes, which constitute the five primary taste categories.

### Cooling Agents

A variety of chemicals produce cooling and refreshing sensations. Tobacco industry documents obtained from Brown & Williamson (1990, p. 1) state that, “Cooling agents are materials that give a cool feeling when in contact with the skin or mucous membrane, especially those of the mouth, nose, and throat of the human body. The cooling effect is not only caused by a latent heat of its evaporation, but also by its direct chemical action on the thermal sensitive receptors of the human body.”

Menthol is one of the most widely known and frequently used cooling chemicals because it has cooling, refreshing, flavorant, and pain-blocking sensory effects. Menthol also has analgesic properties and acts as an antitussive (cough suppressant) and counterirritant (Laude et al. 1994; Proudfoot et al. 2006; Willis et al. 2011; Ha et al. 2015). Table 3.4 lists cooling agents, many of which are discussed in this chapter and are used in tobacco products. For example, “cooling agent 10” or 3-1-(p-methane-3-yloxy)-1,2-propanodiol, has a slight minty odor. Evidence from tobacco industry documents show that this chemical has been sprayed on tobacco, rolled into the cigarette paper, and used to cause a cooling sensation in the mouth when smoked. Cooling chemicals, even those without a taste or odor, have the potential to increase the appeal of tobacco products, facilitate their use, and contribute to tobacco-related health disparities (Rising and Alexander 2011; Jabba et al. 2022; Leventhal et al. 2022).

Table 3.4 Compounds that provide cooling, minty, and other sensations^a^ used in tobacco products, food, cosmetics, personal care products, and other consumer products

Compound | Description | FEMA GRAS number | CAS registry number
Menthol stereoisomers
(-)-Menthol = L-menthol = (1R,2S,5R)-5-methyl-2-propan-2-ylcyclohexan-1-ol | - Most commonly used in cigarettes, often naturally derived from cornmint (Mentha arvensis) oil (also present in peppermint or other mints)^b^; - Clean, minty odor and intense cooling; - L-menthol, the form found in nature, can also be synthetically produced by hydrogenating thymol and then isolating L-menthol but this results in a musty odor; - FEMA flavor profile: mint, cool | 2665 | 2216-51-5
(+)-Neomenthol = D-Neomenthol | - This stereoisomer is produced through hydrogenation of thymol | —^c^ | 63975-60-0
(+)-Isomenthol = D-Isomenthol | - This stereoisomer is produced through hydrogenation of thymol; - No FEMA flavor profile found | 4729 | 3623-52-7
(+)-Neoisomenthol = D-Neoisomenthol | - This stereoisomer is produced through hydrogenation of thymol; - FEMA flavor profile: mint, cool | 2666 | 20752-34-5
(+)-Menthol = D-menthol | - This form is not found in nature; - A less desirable, musty mint odor compared to L-menthol; less cooling | —^c^ | 15356-60-2
(±)-Menthol = D,L-Menthol = Racemic Menthol | - Peppermint odor and taste; - Equal amounts of L-menthol and D-menthol stereoisomers; typically synthetic; - FEMA flavor profile: mint, cool | 2665 | 1490-04-6
D,L-Menthol(±)-propylene glycol carbonate | - FEMA flavor profile: mint, cool | 3992 | 156324-82-2
Menthol derivatives
Menthyl acetate = (5-methyl-2-propan-2-ylcyclohexyl)acetate | - FEMA flavor profile: mint, cool | 2668 | 16409-45-3
Frescolat MGC = L-menthol ethylene glycol carbonate | - Cooling on the skin and neutral taste and flavor; - First patented as a tobacco flavorant, then patented as a general cooling agent; - Used in tobacco products; - No FEMA flavor profile listed | 3805 | 156324-78-6
Frescolat MPC = L-menthol 1- and 2-propylene glycol carbonate | - Cooling on the skin and neutral taste and flavor; - First patented as a tobacco flavorant, then patented as a general cooling agent; - FEMA flavor profile: mint, cool | 3806 | 30304-82-6; 868046-84-8
Carvone-5,6-oxide | - FEMA flavor profile: mint, cooling | 4084 | 18383-49-8
Carvone | - FEMA flavor profile: basil, bitter, caraway, fennel, mint; - Strong minty and cooling or irritant flavor in spearmint that is added to many tobacco products | 2249 | 648-40-1; 2244-16-8; 99-49-0
Carvacrol = 2-methyl-5-(1-methylethyl) phenol | - FEMA flavor profile: caraway, spice, thyme; - Liquid, colorless to pale yellow color; pungent, spicy odor | 2245 | 499-75-2
Menthone = (2S,5R)-5-methyl-2-propan-2-ylcyclohexan-1-one | - FEMA flavor profile: green, fresh, mint; - Minor cooling activity | 2667 | 10458-14-7
2,3-dihydroxy-p-menthane | - Cooling | —^c^ | —^c^
3,3,5-trimethylcyclohexanone glycerol ketal | - Cooling | —^c^ | —^c^
(1R,3R,4S)-3-menthyl-3,6-dioxaheptanoate | - Cooling | —^c^ | —^c^
(1R,2S,5R)-3-menthyl methoxyacetate | - Cooling | —^c^ | —^c^
(1R,2S,5R)-3-menthyl3.6,9-trioxadecanoate | - Cooling | —^c^ | —^c^
(1R,2S,5R)-3-menthyl(2-hydroxyethoxy)acetate | - Cooling | —^c^ | —^c^
(1R,2S,5R)-menthyl 11-hydroxy-3,6,9-trioxaundecanoate | - Cooling | —^c^ | —^c^
3-(L-Menthoxy)-2-methylpropane-1,2-diol | - FEMA flavor profile: mint, cool | 3849 | 195863-84-4
Cooling agent 10 = (-)-Menthoxypropane-1,2-diol = 3-[[5-Methyl-2-(1-methylethyl)cyclohexyl]oxy] propane-1,2-diol | - Cooling; increases saltiness; - Produced by Takasago International Corp (Tokyo, Japan) | —^c^ | 87061-04-9
Other cooling agents
AG-3-5 = Icilin = 1-[2-hydroxyphenyl]-4-[3-nitrophenyl]-1,2,3,6-tetrahydropyrimidine-2-one | - Cooling when in contact with mucous membranes and when ingested; nearly 200-fold more potent coolant than menthol | —^c^ | 36945-98-9
3-methyl-2-(1-pyrrolidinyl)-2-cyclopenten-1-one | - Cooling on oral cavity and skin | —^c^ | 41357-00-0
5-methyl-2-(1-pyrrolidinyl)-2-cyclopenten-1-one | - Cooling on oral cavity and skin | —^c^ | 4933-43-1
2,5-dimethyl-4-(1-pyrrolidinyl)-3[2H]-furanone | - Cooling on oral cavity and skin | —^c^ | 80873-59-2
4-methyl-3-(1-pyrrolidinyl)-2[5H]-furanone | - Cooling on oral cavity and skin | —^c^ | 770-99-0
Commercialized WS coolants
WS-23 = Symcool WS-23 = 2-Isopropyl-N,2,3-trimethylbutyramide = N,2,3-trimethyl-2-(1-methylethyl)-butanamide | - About 75% of the cooling intensity compared with menthol; - With WS-3, one of the two most commonly used carboxamide coolants; - Clean cooling; no taste, bitterness, burn, sting, or tingle; - Used in chewing gum, breath fresheners, confections, oral care, cosmetics, and e-liquids used in e-cigarettes; - FEMA flavor profile: cooling | 3804 | 51115-67-4
WS-3 = Symcool WS-3 = N-Ethyl-p-menthane-3-carboxamide = N-Ethyl-2-isopropyl-5-methylcyclohexane carboxamide = N-Ethyl-5-Methyl-2-(1-Methylethyl)-Cyclohexane Carboxamide | - About 50% greater cooling intensity than menthol; - With WS-23, one of the two most commonly used carboxamide coolants; - Nearly odorless; characterized by a high cooling activity with no side effects, such as burning, stinging, or tingling sensations; - Nearly tasteless with a faint mint taste; good duration of physical cooling; can be used as an insecticide; - Used in chewing gum, breath fresheners, confections, oral care, cosmetics, and e-liquids used in e-cigarettes; - FEMA flavor profile: cooling | 3455 | 39711-79-0
ICE 1500 = mixture of WS-3 and WS-23 | - Combines the instant cooling sensations of WS-23 with the gradual and smooth cooling sensation of WS-3 (Leffingwell 2018); - “Provides saltiness and/or flavor enhancement of about 20–30% in a wide variety of foodstuffs such as salsas, salad dressings and marinades, margarine, soups and bouillons, as well as alcoholic beverages, when used at levels where the cooling sensation is imperceptible or barely perceptible” (Leffingwell 2018) | 3455 and 3804 | 39711-79-0 and 51115-67-4
WS-5 = Symcool WS-5 = (1R,2S,5R)-N-((Ethoxycarbonyl)methyl)-p-methane-3-carboxamide = N-[(Ethoxycarbonyl)methyl)-p-menthane-3-carboxamide = N-(Ethoxycarbonylmethyl)-3-p-menthanecarboxamide | - Four times the cooling intensity of menthol; - Only highly purified version is used for flavoring, otherwise it is very bitter; - FEMA flavor profile: cooling | 4309 | 68489-14-5
WS-12 = Symcool WS-12 = (1R,2S,5R)-N-(4-Methoxyphenyl)-p-menthanecarboxamide = (1R,2S,5R)-N-(4-Methoxyphenyl)-5-methyl-2-(1-methylethyl) cyclohexanecarboxamide | - Virtually nonvolatile, odorless, and tasteless; - Strongest initial cooling and a longer lasting effect compared with other coolants, such as WS-3, WS-23, and WS-5; - “[WS-12] can be used at low levels to impart freshness into berry, citrus, and other fruit flavors in a variety of applications” (Leffingwell 2018); - FEMA flavor profile: cooling | 4681 | 68489-09-8
WS-27 = N-Ethyl-2,2-diisopropylbutanamide | - FEMA flavor profile: cooling | 4557 | 51115-70-9
WS-NA = N-Cyclopropyl-5-methyl-2-is opropylcyclohexanecarboxa mide | - About 50% of the cooling intensity of menthol; - FEMA flavor profile: imparts a cooling sensation | 4693 | 73435-61-7
WS-116 = N-(1,1-Dimethyl-2-hydroxyethyl)-2,2-diethylbutanamide | - In conjunction with warming agents, enhances the warming sensation; - FEMA flavor profile: cooling | 4603 | 51115-77-6
WS-NA = Coolact 5 = 2-(L-Menthoxy)ethanol | - Cooling; - No FEMA flavor profile listed | 4154 | 38618-23-4
WS-14 = N-tert-butyl-p-menthane-3-carboxamide = N-[(Ethoxycarbonyl)methyl)-p-methane-3-carboxamide | - Cooling; - About 75% of the cooling strength of menthol; - Used as a cooling agent in Northwind cigarettes, which were introduced into a test market in 1981; Northwind cigarette test was unsuccessful, and the product was withdrawn from the market^d^; - Commercially available as ICE 4000 | 4309 | 68489-14-5
Other commercially marketed coolants
3-L-Menthoxypropane-1,2-diol | - Cooling; - Creates warming sensation when mixed with vanillyl, butyl ether, ginger extract, capsicum; - FEMA flavor profile: floral | 3784 | 87061-04-9
3-(L-menthoxy)-2-methylpropane-1,2-diol | - Cooling; - Creates warming sensation when mixed with vanillyl, butyl ether, ginger extract, capsicum | —^c^ | 195863-84-4
2,6-Diethyl-5-isopropyl-2-methyltetrahydropyran = 5-isopropyl-2,6-diethyl-2-methyltetrahydro-2H-pyran | - Refreshing effects; - FEMA flavor profile: green | 4680 | 1120363-98-5
trans-4-tert-Butylcyclohexanol | - TRPV1 antagonist that inhibits heat sensation and thus enhances cooling agents; - FEMA flavor profile: earthy, fatty | 4724 | 21862-63-5
2-(p-tolyloxy)-N-(1H-pyrazol-5-yl)-N-((thiophen-2-yl) methyl)acetamide = 2-(4-methylphenoxy)-N-(1H-pyrazol-3-yl)-N-(thiophen-2-ylmethyl)acetamide | - Compound made by biotech company Senomyx (San Diego, California); - FEMA flavor profile: cooling | 4809 | 1374760-95-8
Freshone = 6-isopropyl-3,9-dimethyl-1,4-dioxaspiro[4.5]decan-2-one = 3,9-dimethyl-6-(1-methylethyl)-1,4-dioxaspiro[4.5]decan-2-one | - Refreshing cooling effect with some minty, fruity notes; - FEMA flavor profile: imparts a cooling sensation | 4285 | 831213-72-0
Coolact P = (-)-Isopulegol = Isopulegol = (1R,2S,5R)-5-methyl-2-prop-1-en-2-ylcyclohexan-1-ol | - Highly purified Isopulegol is odorless but imparts a feeling of freshness, crispness, and coolness to citrus-type fragrances; - FEMA flavor profile: mint, cool | 2962 | 89-79-2
Frescolat ML = (-)-Menthyl lactate = L-Menthyl lactate = [(1R,2S,5R)-5-methyl-2-propan-2-ylcyclohexyl] (2S)-2-hydroxypropanoate | - Faintly minty in odor and virtually tasteless; long-lasting cooling effect; - FEMA flavor profile: mint, cool | 3748 | 61597-98-6
Coolact 10 = 3-((-)-Menthoxy)propane-1,2-diol = 3-L-Menthoxypropane-1,2-diol | - Cooling without odor; - FEMA flavor profile: floral; - Made by Takasago International Corp. (Tokyo, Japan) | 3784 | 87061-04-9
Frescolat MGA (levo) = (-)-Menthone 1,2-glycerol ketal = L-Menthone 1,2-glycerol ketal | - Cooling and refreshing, longer lasting sweetness in gum; more common than racemic form; - FEMA flavor profile: mint, cool | 3807 | 63187-91-7
Frescolat MGA (racemic) = D,L-Menthone 1,2-glycerol ketal = (±)-Menthone 1,2-glycerol ketal | - Cooling and refreshing, longer lasting sweetness in gum; - FEMA flavor profile: mint, cool | 3808 | 63187-91-7
(-)-Menthyl succinate = Mono-menthyl Succinate = 4-(5-methyl-2-propan-2-ylcyclohexyl)oxy-4-oxobutanoic acid | - Cooling agent for general use; - Used in tobacco products; - FEMA flavor profile: mint, cool | 3810 | 77341-67-4
Cooler 2 = (-)-Menthyl glutarate = L-Monomenthyl glutarate = 5-[(1R,2S,5R)-5-methyl-2-propan-2-ylcyclohexyl]oxy-5-oxopentanoic acid | - FEMA flavor profile: mint, cool | 4006 | 220621-22-7
Coolact 38D = PMD 38 = p-Menthane-3,8-diol = 2-(2-hydroxypropan-2-yl)-5-methylcyclohexan-1-ol | - Insecticide; - FEMA flavor profile: mint, cool | 4053 | 42822-86-6
Questice = (-)-Menthyl pyrrolidone carboxylate = L-Menthyl pyrrolidone carboxylate = [(1R,2S,5R)-5-methyl-2-propan-2-ylcyclohexyl] (2S)-5-oxopyrrolidine-2-carboxylate | - Produced by reacting (-)-menthol with L-pyrrolidin-2-one carboxylic acid; - First patented as a long-lasting cooling and fresh ingredient used in toothpaste; - Patented as an insect repellent; - FEMA flavor profile: mint, cool | 4155 | 68127-22-0
N,N-Dimethyl (-)-menthyl succinamide = (±)-N,N-Dimethyl Menthyl Succinamide = [(1R,2S,5R)-5-methyl-2-propan-2-ylcyclohexyl] 4-(dimethylamino)-4-oxobutanoate | - Cooling and refreshing on the tongue, palate, and front gums, imparting a fruity flavor with sour undertones; - Long lasting cooling effect; - FEMA flavor profile: imparts a cooling sensation | 4230 | 544714-08-1
L-Menthyl (R,S)-3-Hydroxybutyrate = [(1R,2S,5R)-5-methyl-2-propan-2-ylcyclohexyl] 3-hydroxybutanoate | - FEMA flavor profile: mint, cool | 4308 | 108766-16-1
Ultracool 7 = (-)-Menthyl acetoacetate = L-Menthyl acetoacetate = [(1S,2R,5S)-5-methyl-2-propan-2-ylcyclohexyl] 3-oxobutanoate | - FEMA flavor profile: mint, cool | 4327 | 59557-05-0
(-)-Cubebol = Cubebol = (1R,4S,5R,6R,7S,10R)4,10-dimethyl-7-propan-2-yltricyclo[4.4.0.01,5]decan-4-ol | - Refreshing; - Weak smell and taste; - FEMA flavor profile: spice; - Warm, spicy, naturally cooling mint-like aroma | 4497 | 23445-02-5
Evercool 180 = G-180 = N-P-benzeneacetonitrile menthanecarboxamide | - Cooling; increases saltiness at different levels; - FEMA flavor profile: imparts a cooling sensation | 4496 | 852379-28-3
Evercool 190 = G-190 = (1R,2S,5R)-N-(2-(pyridin-2-yl) ethyl)menthylcarboxamide = N-(2-(Pyridin-2-yl)ethyl)-3-p-menthanecarboxamide | - Cooling; increases saltiness at different levels; - FEMA flavor profile: imparts a cooling sensation | 4549 | 847565-09-7
N-(2-Hydroxyethyl)2,3-dimethyl-2-isopropylbutanamide | - When used in conjunction with other cooling agents (e.g., WS-3), this compound provides superior cooling and flavor properties in confections and chewing gum; - In conjunction with warming agents, it enhances the warming sensation; - FEMA flavor profile: cooling | 4602 | 883215-02-9
N-benzo[1,3] dioxol-5-yl-3-p-menthanecarboxamide | - 100 times more cooling intensity than menthol | —^c^ | —^c^
N-benzooxazol-4-yl-3-p-menthanecarboxamide | - 100 times more cooling intensity than menthol | —^c^ | —^c^
N-(1-isopropyl-1,2-dimethylpropyl)-1,3-benzodioxole-5-carboxamide | - WS-23 analog; - Has about 2.2 times more cooling intensity than 2 ppm of menthol | —^c^ | —^c^
N-(2-ethoxyethyl)-2-isopropyl-2,3-dimethylbutanamide | - WS-23 analog; - Cooling intensities greater than or equal to WS-23 | —^c^ | —^c^
N-4-([1,2,4]triazol-l-yl)-phenyl-3-p-menthanecarboxamide | - 100 times more cooling intensity than menthol | —^c^ | —^c^
N-4-(pyrazol-l-yl)-phenyl-3-p-menthanecarboxamide | - 100 times more cooling intensity than menthol | —^c^ | —^c^
Di-(-)-menthyl glutarate = Dimenthyl Glutarate = bis(5-methyl-2-propan-2-ylcyclohexyl) pentanedioate | - Coolant; - No FEMA flavor profile listed | 4604 | 406179-71-3
(1R,2S,5R)-N-(4-(carbamoylmethyl)phenyl)-menthylcarboxamide = (2S,5R)-N-[4-(2-amino-2-oxoethyl)phenyl]-5-methyl-2-(propan-2-yl) cyclohexanecarboxamide | - Produces long lasting cooling in throat and mouth, with some bitterness; - FEMA flavor profile: cooling | 4684 | 1119711-29-3
2-[2-(p-menthan-3-yloxy) ethoxy]ethanol = 2[2-(p-menthyloxy)ethoxy] ethanol | - Coolant; - No FEMA flavor profile listed | 4718 | 28804-53-7
(1R,2R,4R)-1-(2-Hydroxy-4-methylcyclohexyl)ethanone = 1-(2-hydroxy-4-methylcyclohexyl)ethenone | - Coolant; - No FEMA flavor profile listed | 4742 | 917750-72-2
5-methyl-4-(1-pyrrolidinyl)-3-[2H]-furanone | - Cooling, odorless | —^c^ | —^c^
4,5-dimethyl-3-(1-pyrrolidinyl)-2[5H]-furanone | - Cooling, faintly mint-like | —^c^ | —^c^
4-methyl-3-(1-pyrrolidinyl)-2[5H]-furanone | - Cooling, odorless | —^c^ | 770-99-0
Eucalyptol = 1,3,3-trimethyl-2-oxabicyclo[2.2.2]octane 1, 8 Cinole | - Compound found in abundance in Eucalyptus globulus (southern blue gum); - Cooling, tingling, spicy; - FEMA flavor profile: camphor, cool, eucalyptol, mint | 2465 | 470-82-6
D-Sorbitol = (2R,3R,4R,5S)-hexane-1,2,3,4,5,6-hexol | - Sweetener that exhibits cooling when mixed with warm saliva; - No FEMA flavor profile listed; - Structural isomer of mannitol | 3029 | 50-70-4
Mannitol = (2R,3R,4R,5R)-hexane-1,2,3,4,5,6-hexol | - Sweetener that exhibits cooling when completely dissolved^e^; - Can mask unpleasant or bitter tastes; - Structural isomer of sorbitol | —^c^ | 69-65-8
Urea | - Short cooling effects in fragrances | —^c^ | 57-13-6
Methyl salicylate = Methyl 2-hydroxybenzoate | - Flavor compound is naturally found in wintergreen oil from Gaultheria species that is commonly used in smokeless tobacco products; - Has irritant effects, can desensitize irritant pathways and act as a permeation enhancer; - Usually used in lower concentration; however, in high enough concentration, this compound is harmful if inhaled, ingested, or absorbed dermally; - FEMA flavor profile: almond, caramel, peppermint, sharp | 2745 | 119-36-8
Ethyl salicylate = Ethyl 2-hydroxybenzoate | - Artificial flavor compound often used in smokeless tobacco products; - Formed by condensation reaction of salicylic acid and ethanol; - Has a pleasant odor that resembles wintergreen and is also used in perfume and as an artificial flavor | 2458 | 118-61-6
D-Camphor = (1R,4R)-1,7,7-trimethylbicyclo[2.2.1]heptan2-one | - Found naturally in camphor laurel tree (Cinnamomum camphora); - FEMA flavor profile: camphor, earth, pine, spice | 2230 | 464-49-3
DL-Camphor = 1,7,7-trimethylbicyclo[2.2.1] heptan-2-one | - FEMA flavor profile: mint, cool | 4513 | 76-22-2
Cinnamomum camphora whole = Camphor Japanese white oil = Camphor oil | - Anti-inflammatory and analgesic properties; - Herbal minty odor; - No FEMA flavor profile listed | 2231 | 8008-51-3
Thymol = 2-Isopropyl-5-methylphenol = Thyme camphor = 5-Methyl-2-isopropylphenol | - Herbal odor, like thyme; sweet-medicinal, herbaceous, warm, aromatic odor; - FEMA flavor profile: spice and wood | 3066 | 89-83-8
Capsaicin | - Found naturally in chili peppers; - Acts as an analgesic that blocks pain and is a TRPV1 agonist; - Pungent odor and burning taste; - No FEMA flavor profile listed | 3404 | 404-86-4
Nonanoyl 4-hydroxy-3-methoxybenzylamide = Nonivamide = N-Vanillylnonanamide | - Used as a topical analgesic and flavoring ingredient; - Agonist of TRPV1 receptor; - Parent compound is vanillylamide; - FEMA flavor profile: savory | 2787 | 2444-46-4
(E)-3-benzo[1,3]dioxol-5-yl-n,n-diphenyl-2-propenamide = N-[2-(methoxymethyl)-4-methylpentyl]-3,4-dimethylbenzamide | - Chemically synthesized; - New chemical evaluated; intended to be used as a flavoring substance in specific categories of food^f^; - Cooling properties; minty, burning, tingling, fresh, fruity notes^f^; - No FEMA flavor profile listed | 4788 | 1309389-73-8
N-ethyl-5-methyl-2-(1-methylethenyl) cyclohexanecarboxamide | - Minty odor; - Cooling sensation on skin^g^; - No FEMA flavor profile listed | 4808 | 1582789-90-9
Gamma-aminobutyric acid = 4-aminobutyric acid = GABA | - Savory, meat-like aroma; - FEMA flavor profile: cooked and roasted, fruit | 4821 | 56-12-2
2,4-dihydroxy-n-[(4-hydroxy-3-methoxyphenyl)methyl] benzamide = 2,4-dihydryxybenzoic acid vanillylamide | - No FEMA flavor profile listed | 4835 | 877207-36-8
(E)-3-(3,4-dimethoxyphenyl)-n-[2-(4-methoxyphenyl)-ethyl]-acrylamide | - FEMA flavor profile: umami | 4877 | 76733-95-4

Sources: Leffingwell (2009; 2018), Leffingwell and Rowsell (2014), FEMA (n.d.b), PubChem (n.d.), and Symrise (n.d.), Food and Agricultural Organization of the United Nations (n.d.) unless noted specifically otherwise.

Notes: Cooling agents can have sensory effects of cooling, activating various receptors in the body, with or without a minty taste. A substance’s food additive approval or GRAS status is not applicable to inhalation. CAS = Chemical Abstracts Service; FEMA = Flavor and Extract Manufacturers Association; GRAS = generally recognized as safe; ppm = parts per million; WS = Wilkinson Sword.

a Select additional compounds, such as capsaicinoids, are included.

b The FEMA flavor library also lists various types of mint flavors separately, including peppermint oil (FEMA 2848), spearmint oil (FEMA 3032), scotch spearmint oil (FEMA 4221), curly mint oil (FEMA 4778), and ginger mint (FEMA 4811).

c Not available.

d Daylor (1982).

e Kearsley and Deis (2006) and Song and Vieille (2009).

f Younes and colleagues (2022).

g Parchem (n.d.).

#### Production of Menthol and Other Cooling Agents

The majority of commonly used flavor chemicals and other additives in tobacco products are produced by chemical synthesis (Schwab et al. 2008; Dionísio et al. 2012). This includes menthol, which is used for its medicinal analgesic and anesthetic properties in cosmetics, household products, oral care products, chewing gum, and various confectionary products. Menthol (C10H20O) is one of the few chemicals that is used as a flavor, fragrance, and for its pharmacologic effects on the sensory nerves and muscle system (Figure 3.2). As the active ingredient in some over-the-counter and prescription drugs, menthol mildly numbs the throat and is used in cough drops and similar products to relieve sore throat and other analgesic purposes; for its antitussive properties; and as an antipruritic (also known as an abirritant or counterirritant) to relieve itching and localized irritation. Approximately one-fourth of the world’s menthol production is used in tobacco products, surpassed only by its use in oral hygiene and pharmaceutical products (Clark 2007).

Figure 3.2 Structural formulas for L-menthol and D-menthol

Notes: Left: L-menthol (left) is a minty and cooling menthol isomer added to cigarettes and other tobacco products. L-menthol is also known as levo menthol, L(-)menthol, or (-)-menthol. Right: D-menthol is a minor isomer in mint oil, with no cooling effect and a phenolic odor.

Structural formulas are described in the notes for the figure.

Menthol can impart on the skin perceptions of cooling or warming sensations at a concentration of less than 1%; for oral cooling, the threshold for menthol is about 0.3 μg (Rowe 2005). This sensation results from stimulation of thermoreceptors and not temperature changes on the skin or in the body (Eccles 1994). Laboratory analyses have detected menthol in relatively small quantities (0.002–0.07 mg/cigarette, an average of 0.0183 mg/cigarette or 18 μg/cigarette) in cigarettes that are marketed in the United States as nonmenthol or regular cigarettes (Ai et al. 2016). Peppermint oil, one of two plant extracts from which menthol is derived, usually contains 40–50% L-menthol, 22% menthone, 5% eucalyptol (1,8-cineole), and small amounts of other menthol isomers and related compounds (Nair 2001; National Library of Medicine 2019). Menthol produces the rapid onset of a cooling sensation (Rowe 2005). The cooling effect of L-menthol, a menthol isomer, is 45 times stronger than the cooling effect of D-menthol, and L-menthol is the major menthol stereoisomer added to tobacco products (Eccles 1994; Rowe 2005; Chen et al. 2011). L-menthol is primarily responsible for interacting with the TRPM8 cold- and menthol-sensing receptor. Unlike L-menthol, which produces a cooling sensation when it binds to TRPM8 (Chuang et al. 2004; McKemy 2007), D-menthol does not induce a cooling sensation and instead irritates the skin (Gusain et al. 2017). L-menthol stimulates TRPM8 severalfold more than other menthol stereoisomers (Behrendt et al. 2004; Bandell et al. 2006).

Companies such as Symrise (formerly Haarmann and Reimer), Badische Anilin und Soda Fabrik (BASF), and the Takasago International Corporation mass produce menthol and synthetic menthol for multiple commercial products. Commercial menthol was first sourced by extracting natural plant materials from Mentha piperita, the peppermint plant. Of the eight possible stereoisomers of menthol, peppermint oil contains L-menthol almost exclusively. Only trace amounts of other stereoisomers are found in peppermint oil. L-menthol has a minty odor and cooling effect often associated with peppermint, whereas the other stereoisomers have less desirable odors and less cooling effects (Leffingwell 2009). Peppermint oil is largely used in gum, toothpaste, mouthwash, and other oral hygiene products (Eccles 1994; Leffingwell 2009). The second of the two plant extracts from which menthol is derived for mass-scale production, corn mint or Mentha arvensis, initially cultivated in Japan, produces higher yields of L-menthol than peppermint oil. Brazil used to be a major source of corn mint-derived L-menthol, but India and China currently produce the majority of Mentha arvensis-derived L-menthol (Leffingwell 2009; Singh and Kumar 2021; Semwal n.d.). Various other sources—such as citronella, eucalyptus oil, Indian turpentine oil, and thymol—can also be used to produce menthol (Eccles 1994; Leffingwell 2009).

#### Mass Production of Menthol as a Cooling Agent for Use in Tobacco Products

In the 1960s and 1970s, the production of naturally sourced menthol often could not satisfy the increasing demand from the tobacco industry and other industries using menthol, leading to large fluctuations in price and to supply problems (Leffingwell 2009). Tobacco manufacturers started partnering with flavor manufacturers that were seeking synthetic routes to produce menthol. Documents from R.J. Reynolds suggest that since 1975, the company’s products have used synthetic menthol (R.J. Reynolds 1977). A 1992 memorandum from Lorillard stated that “60% synthetic menthol and 40% Brazilian menthol … is a standard mixture used in our mentholated cigarettes” (Viso 1992, p. 3). However, the current ratios of synthetic and natural menthol are unpublished.

In 1983, Takasago International Corporation, one of the world’s largest fragrance and flavor producers, started using a stereoselective process to efficiently produce synthetic L-menthol on a large scale (Emura and Matsuda 2014). The stereoselective process started with myrcene and used rhodium and ruthenium catalysts to produce L-menthol. Later, the process was optimized using alternative catalysts to produce higher yields (Maeda et al. 2012). For example, German-based Symrise AG’s process starts from meta-cresol, which is sourced from coal tar or toluene, resulting in a racemic mixture, a mixture that has equal amounts of L- and D-menthol, and is followed by a stereoselective separation step (Hopp 1989).

Prices for natural menthol continued to rise in the 1990s, a frequent complaint by the tobacco industry, making synthetic menthol more price competitive (Juentgen and Tutte-Olm 1996). Global production of natural and synthetic menthol increased from 12,000 tons in 1989 to more than 48,000 tons in 2016, with revenue of approximately $775 million in 2016 (QYResearch 2017). The production of menthol, the majority of which is for oral hygiene products (Leffingwell 2009), was expected to exceed 61,000 tons in 2022, with estimated revenue of $932 million (QYResearch 2017). A 2020 market research report estimated that global production of menthol cigarettes would grow by 3% from 2021 to 2026 (IMARC Group 2020).

Data from the National Survey on Drug Use and Health indicate that the leading brands of menthol cigarettes from 2014 to 2019 were Newport and Marlboro, comprising more than 50% of the menthol cigarette market (Miller Lo et al. 2022). The Newport brand was first owned by Lorillard Tobacco Company and was then acquired by R.J. Reynolds in 2014. Newport is the most commonly used menthol brand among African American people who smoke; more than half of people who used Newport in 2019 were African American (Miller Lo et al. 2022). Additionally, more than 50% of people who used Newport in 2019 had incomes lower than $30,000 per year (Miller Lo et al. 2022). The Marlboro brand includes both menthol and nonmenthol varieties and is owned by Philip Morris/Altria. In addition to Newport and Marlboro, many cigarette brands offer menthol varieties, such as Pall Mall, Camel, American Spirit, L&M, Winston, Eagle, Basic, Kool, Pyramid, USA Gold, 305s, Virginia Slims, “roll your own” tobacco, and others (Miller Lo et al. 2022). FDA’s proposed rule to prohibit menthol as a characterizing flavor in cigarettes would have a significant impact on tobacco use among all people who initiate smoking with or currently smoke menthol cigarettes, including in particular populations who disproportionately use menthol cigarettes, such as youth, women, African American people, members of the LGBTQI+ (LGBT, queer or questioning, intersex, and other sexual orientation and gender identities) community, and people with lower incomes (see Chapter 2).

#### Mint Flavorants and Cooling Agents

In addition to menthol, other chemicals can produce crispness and cooling or refreshing sensations with or without a minty or menthol taste or odor. For example, menthone, a ketone analog of menthol, is often detected in tobacco products and produces a strong minty odor (Figure 3.3) (Schmitz et al. 2015; Krüsemann et al. 2017). Menthone has the potential for transdermal drug delivery (Zhao et al. 2001; Brain et al. 2006; Kamatou et al. 2013). It is also used in chewing gum and candy (Dionísio et al. 2012). Menthone and its derivatives have cooling effects and some are marketed under the trade name Frescolat (Leffingwell 2018).

Eucalyptol (1,8-cineole), known for its presence in the leaves of the eucalyptus tree, is present in mint oil and other essential oils (Figure 3.3) (National Center for Biotechnology Information n.d.). It emits a eucalyptus odor, a minty smell, and has a mild cooling effect.

Carvone, the minty flavorant in spearmint, can also be found in a wide variety of mint- or menthol-flavored tobacco products, including cigarettes, e-cigarettes, and moist snuff and snus (Figure 3.3). Two stereoisomers of carvone exist: (S)-(+)-carvone is the major flavorant in caraway seeds, and (R)-(-) carvone is the major flavorant in spearmint oil and the main component responsible for the minty aroma in that plant (Dionísio et al. 2012). Carvone emits an intense minty odor that is more pungent than menthol’s odor. Similar to menthol, carvone has been identified in e-cigarette products that have a variety of flavor descriptors (Jabba et al. 2022).

Figure 3.3 Structural formulas for menthone, eucalyptol, carvone, and pulegone

Notes: Top Left: (-)-Menthone is a component of mint oil, with a strong minty odor and minor cooling activity. Top Right: Eucalyptol is the cooling and soothing agent in eucalyptus oil. Bottom Left: Carvone is the strong minty and cooling or irritant flavor in spearmint that is added to many tobacco products. Bottom Right: Pulegone is a potential carcinogenic constituent of mint oils and is present in several mint- and menthol-flavored tobacco products as an adulterant, when mint oil acts as the source of menthol.

Structural formulas are described in the notes for the figure.

Although these compounds may exhibit a minty smell and cooling effect, there is no association between the mint smell and the cooling effects (Eccles 1994). Compounds that lacked a menthol or minty odor but retained a cooling effect were first developed in the 1970s by Wilkinson Sword (WS), a company that produces shaving products (Watson et al. 1978). Some chemicals in the WS-series distinguished themselves by having cooling properties without a minty odor and with less irritancy than menthol (Watson et al. 1978). These agents are now widely used in chewing gums, confections, shaving products, and other skin and hair care products.

Following the development of the original WS series of synthetic cooling agents, many other cooling agents were developed for additional consumer products and foods. Some of these agents can produce cooling on different parts of the body (e.g., skin, mouth, throat, tongue) and can impart fruity or citrus flavors when used at certain levels (Table 3.4).

The effects of chemicals listed in Table 3.4 may differ in intensity and duration. For example:

- WS-12 [(1R,2S,5R)-N-(4-Methoxyphenyl)-p-menthane carboxamide] is tasteless and odorless and can be used at low levels to impart freshness in berry, citrus, and other fruit flavors. It is the strongest of the WS cooling agents and has a longer lasting effect than WS-3, WS-5, and WS-23 (Leffingwell and Rowsell 2014).
- (-)-Menthyl (S)-3-hydroxybutyrate has a cooling effect but is odorless and tasteless (Leffingwell and Rowsell 2014).
- Frescolat ML [(-)-Menthyl lactate] has a cooling effect and a faintly minty odor, and is virtually tasteless (Leffingwell 2009).

#### Synthetic Cooling Agents in Combustible Cigarettes

Documents from the tobacco industry reveal that a cool-without-menthol concept was discussed before the development of synthetic cooling agents (Hind 1972). In 1974 and 1975, R.J. Reynolds tested among consumers the compounds identified as WS-3, WS-10, WS-14, WS-23, WS-123, and WS-125 for their cooling effects in cigarettes and found that WS-14 [N-([ethoxycarbonyl]methyl)-p-menthane-3-carboximide] was as acceptable to consumers as menthol (Leffingwell and Rowsell 2014). R.J. Reynolds did not pursue commercialization of synthetic cooling agents in cigarettes any further at the time, citing in an inter-office memorandum that the risk that marketing a “cool” but not “menthol” product that used WS-14 or another synthetic cooling agent could draw unwanted attention to tobacco additives, public investigation, or federal regulation (Leffingwell 1975). In the early 1980s, Philip Morris test-marketed a new brand of cigarettes, Northwind, in the St. Louis, Missouri, area (Figure 3.4). Labeled with the slogan “Cools without Menthol,” Northwind contained the odorless cooling compound WS-14 (commercially available as ICE 4000) (Leffingwell 2009). However, the campaign was not successful with consumers, and internal concerns were raised about the toxicity of unknown combustion products of WS-14 and lack of testing (Newman 1981; Daylor 1982).

Since then, several synthetic cooling agents, including WS-3 and WS-23, have been reviewed by FEMA and are included in the FEMA GRAS list (Leffingwell and Rowsell 2014). (As discussed elsewhere in this chapter, a substance’s GRAS status is not a determination that other exposure routes are safe.) A chemical analytic study by Reger and colleagues (2018) detected small amounts of the cooling agents WS-3 and isopulegol in combustible cigarettes marketed in Germany, suggesting that at least some manufacturers are adding these agents to contemporary combustible tobacco products. WS-3, isopulegol, and multiple other synthetic or natural cooling agents were banned as cigarette additives in Germany (German Federal Office of Justice 2017).

Figure 3.4 Synthetic cooling agents added to cigarettes and e-cigarettes

Notes: Top: Synthetic cooling agents WS-3, menthyl lactate and WS-23, found in e-liquids. WS-3 was detected in combustible cigarettes in Germany and is an additive to nonmenthol cigarettes marketed in California after the state’s flavored tobacco product ban in 2022. WS-14 was added to Northwind cigarettes in the 1980s. Bottom: Advertisement for the Northwind cigarette brand, containing WS-14, test marketed by Philip Morris in 1981. Newport Non-Menthol, Newport EXP Non-Menthol, and Camel Crisp, which were marketed by R.J. Reynolds in California beginning in December 2022 with synthetic cooling agent WS-3 as an additive.

Structural formulas, advertisement, and other imagery are described in the notes for the figure.

In December 2022, California’s law restricting flavored tobacco sales, including menthol cigarettes, took effect (Public Health Law Center 2022). Prior to the restrictions, R.J. Reynolds immediately began marketing cigarettes containing synthetic coolants as “nonmenthol” (Craver 2023) (Figure 3.4). For example, for varieties of the Newport (Newport Non-Menthol Green, Newport EXP) and Camel (Camel Crisp) brands, the ingredient lists from R.J. Reynolds specifically include N-tert-butyl-p-menthane-3-carboxamide (i.e., WS-3) (R.J. Reynolds Tobacco Company 2023). The availability of these products has the potential to undermine the health impact of menthol cigarette restrictions. On April 25, 2023, the California Attorney General issued notices to the tobacco companies marketing these products, R.J. Reynolds and ITG Brands LLC, determining “that each of these Reviewed Products is presumptively FLAVORED under the California flavor ban law” (State of California Department of Justice 2023, p. 1). R.J. Reynolds filed a lawsuit against the California Attorney General on May 11, 2023, asking the notices to be rescinded (Reynolds American 2023).

### Wintergreen Flavor and Methyl Salicylate

Wintergreen is a popular flavor in smokeless tobacco products, including snuff and snus. Methyl salicylate, which is the flavor compound in wintergreen natural oil (Figure 3.5), has counterirritant effects, can desensitize irritant pathways, and can act as a permeation enhancer (Hassan et al. 2010; Moghadam et al. 2013). It is widely used as a topical analgesic in creams. Methyl salicylate is toxic and can be lethal if, for example, it is ingested by children as part of wintergreen oil or is used excessively by athletes as a topical application (Anderson et al. 2017). Levels of methyl salicylate in smokeless tobacco products are substantially higher than such levels in the highest methyl salicylate-containing confectionary products (Chen et al. 2010). Although it has a FEMA GRAS designation for food products, ingestion of methyl salicylate via smokeless tobacco products can exceed recommended safety levels for food (Chen et al. 2010). Methyl salicylate is covered in more detail in the discussion of methyl salicylate as a smokeless tobacco additive later in this chapter.

Figure 3.5 Structural formulas for analgesic and anesthetic flavors

Notes: Left: Methyl salicylate, the wintergreen flavor, is widely popular in smokeless tobacco products, such as moist snuff and sinus, and is also added to some e-liquids. Methyl salicylate has analgesic and counterirritant properties. Right: Eugenol, the clove flavor, is also present in some e-liquids and has anesthetic and cooling properties.

Structural formulas are described in the notes for the figure.

### Eugenol and Other Clove-Derived Flavors

Eugenol and its derivatives, such as methyl eugenol, are derived from clove and have both cooling and local anesthetic effects (Figure 3.5). Eugenol is used as a dental anesthetic and may dampen the irritating effects of smoke in the respiratory system (Roemer et al. 2014). Clove cigarettes are highly popular in Indonesia and were sold in the United States until 2009, when the 2009 Tobacco Control Act prohibited the sale of cigarettes with a characterizing flavor other than menthol or tobacco.

### Sweet, Candy, and Fruit Flavors

As is the case with chemicals with mint and cooling effects, sweeteners have been used in conventional commercial tobacco products for decades, and sweet flavors have become more common over time in such products as cigars, hookah tobacco, e-cigarettes, and smokeless tobacco (Scott-Sheldon and Stroud 2018; Ali et al. 2020; Delnevo et al. 2021a; Wang et al. 2022b). Sweet is one of five basic tastes and is derived from both natural sugars and synthetic sweeteners. Different sugars produce different levels of sweetness. For example, fructose is sweeter than sucrose (table sugar). Sugars are also naturally found in the tobacco leaf. The blending of various types of tobacco, combined with sweetener additives, can influence the sweet taste of a tobacco product that is not advertised as having a characterizing flavor other than tobacco.

Tobacco products widely use natural sweeteners, including sucrose sourced from sugar cane or sugar beets (Figure 3.6). For example, R.J. Reynolds’ ingredient lists commonly include “sugars” for combustible cigarettes and “sucralose” for smokeless tobacco products (R.J. Reynolds Tobacco Company n.d.). Tobacco casings also contain other natural sweeteners, such as licorice (Carmines et al. 2005). The sweetness of licorice comes from glycyrrhizin, which has been detected in a range of tobacco products (Figure 3.6). Glycyrrhizin is a saponin natural product, known for its detergent-like and gelling actions. Excessive consumption of glycyrrhizin can lead to hypertension (Nazari et al. 2017; Deutch et al. 2019) and hypokalemia-induced symptoms, such as muscle cramping or cardiac arrythmias (Nazari et al. 2017). Glycyrrhizin is 30 to 50 times as sweet as sucrose (Ajagannanavar et al. 2014).

Figure 3.6 Structural formulas for natural sweeteners in tobacco products

Notes: Sugars, such as sucrose (table sugar) and glucose, are added to cigarettes, chewing tobacco, and snuff. Glycyrrhizin, a natural sweetener in licorice, is added to casing used in cigarettes and cigars. Glycyrrhizin is 30–50 times as sweet as table sugar.

Structural formulas are described in the notes for the figure.

The use of saccharin as a sweetener in cigarettes dates back to the 1890s when the tobacco industry began using it as an ingredient in chewing tobacco (Tilley 1985). Saccharin is a synthetic, high-intensity sweetener that is 200–700 times sweeter than sucrose (FDA 2018a). More recently, sucralose (e.g., Splenda) was added to tobacco products. Sucralose is a chlorinated derivative of sucrose and is approximately 600 times sweeter than sucrose (FDA 2018a). The presence of acesulfame potassium (acesulfame K or Ace-K) and aspartame has been reported in tobacco products but not as frequently as reported for other artificial sweeteners (Figure 3.7). When heated, these artificial sweeteners are less stable than sucrose, lessening the effects of the sweet taste. The safety of inhaling combusted or aerosolized artificial sweeteners has not been established. As explained previously, a substance’s food additive approval or GRAS status is not applicable to the inhalation of tobacco products or combustible tobacco products.

Figure 3.7 Synthetic, high-intensity sweeteners added to tobacco products

Notes: Saccharin is added to traditional smokeless products, such as moist snuff, and in the mouthpieces and wrapping paper of flavored cigarillos and little cigars. Sucralose is added to snus at very high levels, producing intense sweetness. Acesulfame K is added to some cigarillos and the wood mouth pieces of little cigars. Aspartame is found in some snus and snuff products and in cigarillos.

Structural formulas are described in the notes for the figure.

### Other Flavor Chemicals

Many other flavorants are used in tobacco products, including the tobacco flavor itself. Because of the large number of flavorants, only a few of those most commonly used are mentioned here. Vanillin—the vanilla flavor (Brown et al. 2014)—was one of the first chemical compounds commercially produced in the mid-1800s. Using coniferin as a precursor, synthetically produced vanillin was first sold by the company Haarmann & Reimer, now Symrise, in 1874 (Tiemann and Haarmann 1874; Reimer 1876). Later, vanillin was synthesized from wood lignin, a byproduct of the wood pulp industry. Today, the large majority of synthetic vanillin is produced using a petrochemical process, with guaiacol as a precursor (Hocking 1997). Vanillin is one of the most widely used flavorants added to ice cream, chocolate, baked goods, confections, and beverages. It is considered a sweet-associated flavor. Ethyl vanillin, one of the first synthetic derivatives of a natural flavorant, is three times as potent as vanillin and is often used together with vanillin. Vanillin and ethyl vanillin are the most frequently detected flavorants in e-cigarettes. These compounds were found in 50% of e-liquids marketed in the United States and in more than 30% of those marketed outside the United States (Tierney et al. 2016; Krüsemann et al. 2020). Vanillin combined with other flavors like cherry has been added to little cigars by injecting it by hand into the cigar (Osmalov 1970).

Little is known about the physiological and pharmacological effects of vanillin beyond its role as a flavorant. In rodent experiments, vanillin given orally at a high dose was found to have antidepressant behavioral effects, inhibiting monoamine oxidase (MAO) (Shoeb et al. 2013; Xu et al. 2015). Vanillin- and ethyl vanillin-containing e-liquids also inhibited MAO. However, animals inhaling vanillin did not display any changes in behavior (Ueno et al. 2019).

Cinnamaldehyde was the first chemical to be isolated for use as a flavor and a fragrance (Hajinejad et al. 2020). Fruit and berry flavors often come from such chemicals as benzaldehyde, raspberry ketone, linalool, geraniol, limonene, benzyl alcohol, and ethyl acetate and other esters (Figure 3.8).

Carotenoid-related flavors include damascenone (Figure 3.9), which is used to generate tobacco flavors in such products as e-cigarettes. How “tobacco flavor” and “tobacco” are treated as characterizing flavors will have implications for any regulations that reference such characterizing flavors. Such implications may include efforts to exploit what might be seen as potential regulatory loopholes because some tobacco products that are marketed as tobacco flavor include non-negligible concentrations of flavor additives. Gas chromatography and mass spectrometry analysis have identified the presence of numerous flavor chemicals in tobacco-flavored e-liquids, including beta-damascenone, maltol, ethyl maltol, benzyl alcohol, ethyl acetate, ethyl butyrate, vanillin, ethyl vanillin, and other minor constituent flavor chemicals (Tierney et al. 2016). These flavor chemicals were found in concentrations that could not be obtained simply by using tobacco extracts (Tierney et al. 2016), meaning that they were added to the e-liquids through other means. However, such findings do not apply to all e-liquids. Similar research conducted on two tobacco flavor styles of JUUL, a popular cartridge-based e-cigarette brand, found “negligible concentrations” of total flavor chemicals, with low levels of benzyl alcohol in Classic Tobacco JUUL and “negligible” flavor chemicals in Virginia Tobacco JUUL (Omaiye et al. 2019).

Concept flavor-named tobacco products, which are flavored products described with terms that do not expressly refer to flavors, such as “purple” or “jazz,” are discussed further in the section “Cigars, Cigarillos, and Little Cigars” of this chapter. Concept flavor-named cigarette products are also sold in the United States. Examples of cigarettes marketed as nonmenthol include Camel Crush Oasis Blue capsule cigarettes, which is described as “tropical oasis” (State of California Department of Justice 2023), and Newport EXP Mix cigarettes, which is described as “balanced and flavorful” (Figure 3.4). Capsule cigarettes are discussed later in this chapter.

Figure 3.8 Chemicals in fruity, sweet, and floral flavors

Notes: A large variety of fruit flavors is used in tobacco products, including e-cigarettes, cigarillos, little cigars, and smokeless products. These flavors are often identical to the flavor chemicals in natural fruit and stimulate the olfactory system. Some flavorants, including benzaldehyde and raspberry ketone, are aldehydes and may cause irritation and other toxicologic effects when present at higher concentrations and inhaled. Other flavorants include esters or alcohols.

Structural formulas are described in the notes for the figure.

Figure 3.9 Candy, baked goods, sweet, and tobacco flavors

Notes: Vanillin, the vanilla flavor is contained in a wide range of e-liquids, as a characterizing flavor, or as a flavor note to cherry and other fruit flavored mixes. Pyrazines confer chocolate, cocoa, and coffee flavor notes, and ethyl maltol has an intense cotton candy or caramel flavor. Cinnamaldehyde is the major cinnamon flavor. Damascenone is found in many tobacco flavored e-liquids.

Structural formulas are described in the notes for the figure.

In addition, pyrazines, chocolate, and coffee flavors are added to e-liquids, processed tobacco leaves, and cigarette and cigar casings. Pyrazines are one of the most frequently used additives for enhancing flavors in conventional cigarettes (Leffingwell et al. 1972). Pyrazines are a family of N-heterocyclic compounds that can also be derived from tobacco leaves (Leffingwell et al. 1972; Alpert et al. 2016) and make smoking more palatable by reducing sidestream odor, irritation, and the harshness of nicotine (Connolly et al. 2000; Alpert et al. 2016). Pyrazines, such as 2,5-dimethylpyrazine, are added to tobacco products to impart chocolate or coffee flavors. 2,5-dimethylpyrazine used in e-liquids was shown to elicit respiratory epithelial cell damage, raising concerns for people who use e-cigarettes long term (Sherwood and Boitano 2016). Data from tobacco industry documents show that pyrazines have been used to optimize nicotine delivery and dosing and to reinforce smoking behavior by stimulating olfactory receptors (Alpert et al. 2016). Thus, pyrazine additives may contribute to difficulty quitting among people who smoke.

### Additional Chemical Additives

Additional chemicals, including levulinic acid and benzoic acid, may also be added to tobacco products to reduce the harshness of nicotine and facilitate the uptake of tobacco products. Tobacco industry documents reveal that levulinic acid has been used to raise nicotine yields in cigarettes and increase consumer perceptions of smoothness and mildness (Keithly et al. 2005). Specifically, levulinic acid lowers pH in tobacco smoke and reduces sensation in the upper respiratory tract, which allows for deeper smoke inhalation and may facilitate nicotine binding to neurons that would otherwise not respond to nicotine (Keithly et al. 2005). Further, pod-based e-cigarettes, such as JUUL, deliver nicotine protonated with benzoic acid, instead of freebase nicotine, which lowers pH to allow for greater nicotine delivery and less harshness (Ghosh et al. 2021). Laboratory studies suggest that nicotine salt-based e-liquids (e.g., JUUL) cause cytotoxicity, exerting biological effects that surpass the expected effects of freebase nicotine (Omaiye et al. 2019; Ghosh et al. 2021; Zhang et al. 2021). Nicotine salts are used in a variety of tobacco products, including oral nicotine pouches (Stanfill et al. 2021).

### Flavor Chemicals and Other Additives in Various Categories of Tobacco Products

Following the implementation of the Tobacco Control Act, which prohibited characterizing flavors (other than tobacco and menthol) in cigarettes, sales of capsule cigarettes and flavored noncigarette tobacco products—such as flavored cigars (including little cigars and cigarillos) and e-cigarettes—increased (Delnevo et al. 2017; King et al. 2018; Rossel 2018; Moodie et al. 2019). The next section discusses various products and their relationships to tobacco-related health disparities.

#### Capsule Cigarettes

Capsule cigarettes contain a flavorant-filled capsule in the cigarette filter; people who use these products apply pressure to the filter to break the capsule and release a burst of flavor into the smoke. Capsule cigarettes were developed and introduced in Japan in 2007 but are now marketed worldwide (Kahnert et al. 2012; Thrasher et al. 2016). Moreover, capsule cigarettes are the fastest growing segment of the combustible tobacco market (Rossel 2018; Moodie et al. 2019). The flavor company Symrise is cited as a source for flavor-filled capsules in Philip Morris cigarettes (Pithawalla 2007). In the United States, R.J. Reynolds markets menthol-flavored capsule cigarettes under the Camel Crush brand. Outside the United States, capsule cigarettes are marketed in many different flavors, including mint, menthol, and fruit. Double-capsule designs marketed outside the United States allow consumers to choose two flavors in one cigarette, with one popular choice being a mint or menthol capsule plus a fruit-flavored capsule (Abad-Vivero et al. 2016; Thrasher et al. 2016). Flavor capsules are also available in filters for “roll your own” and make-your-own cigarettes, as well as in cigars, cigarillos, and heated tobacco products (Booth 2018; Moodie et al. 2018; Cho and Thrasher 2019).

Nonmenthol Camel Crush Oasis capsule cigarettes were introduced by R.J. Reynolds following California’s prohibition on the sale of flavored tobacco products—including menthol-flavored products—which took effect in December 2022 (Craver 2023; R.J. Reynolds Tobacco Company 2023). The packaging for the Oasis Blue product includes the descriptors “Tropical Oasis” and “One Crush for a Smooth Tropical Oasis;” packaging for the Oasis Green product states “One Crush—Non-Menthol to a Tropical Oasis;” and packaging for the Oasis Silver product states “One Crush for a Mellow Tropical Oasis” (State of California Department of Justice 2023), suggesting that each product delivers different multisensory flavor experiences.

Cigarette consumption declined between 2008 and 2020, and reductions were greater for nonmenthol cigarettes, which has been attributed in part to the introduction of menthol capsule cigarettes (Delnevo et al. 2022). Sales of menthol capsule cigarettes increased rapidly from 2008 to 2010; sales growth continued at a slower pace from 2010 to 2014 and then plateaued from 2014 to 2020 (Delnevo et al. 2022). Flavor ingredients for menthol capsule cigarettes include menthol, menthone, eucalyptol, and isopulegol (Kahnert et al. 2012; Kim et al. 2018). Sales, distribution, and target marketing of capsule cigarettes marketed as nonmenthol will be important to monitor.

Disparities in the use of capsule cigarettes have been observed in the United States by age and by race and ethnicity. According to data from the 2013–2014 Population Assessment of Tobacco and Health (PATH) Study, capsule cigarettes were the usual cigarettes smoked by 9.4% of young adults (18–24 years of age) who smoked compared with less than 1% of adults 44 years of age and older who smoked (Emond et al. 2018). Among young adults 18–24 years of age who smoked, use of flavored capsules was highest among those who were Hispanic (17.3%), followed by non-Hispanic White (8.4%) and non-Hispanic Black (3.2%) people.

According to a 2012–2014 study in the United States, Mexico, and Australia, 5% of people who smoked used capsule cigarettes (Thrasher et al. 2016). In various market studies, participants have deemed capsule cigarettes as being technologically more advanced and providing a fresher feeling than conventional cigarettes (Moodie et al. 2015, 2018). Correspondingly, capsule cigarettes are misperceived to be healthier than and different from conventional cigarettes (Moodie et al. 2018; Talhout et al. 2018). Finally, data from New Zealand suggest that capsule cigarettes (a) appear to be more attractive to people who do not smoke but are susceptible to smoking than to those who do smoke and (b) might be chosen more frequently than other products to initiate smoking (Hoek et al. 2019).

#### Cigars, Cigarillos, and Little Cigars

According to data from the 2023 NYTS, cigars equaled cigarettes as the most commonly used combusted tobacco product among middle and high school students (Birdsey et al. 2023). Cigar smoking in the past 30 days was higher among non-Hispanic Black students (2.3%) than it was among non-Hispanic White students (1.0%) (Birdsey et al., 2023). The prevalence of cigar use was also higher among youth who identified as lesbian, gay, or bisexual than it was among youth who identified as heterosexual or reported being unsure of their sexual orientation (Gentzke et al. 2020). As of March 2024, flavored cigars (including flavored cigarillos and flavored little cigars) were still on the market. However, as noted previously, FDA has proposed a tobacco product standard that would prohibit all characterizing flavors, including menthol but not including tobacco flavor, in cigars (including cigarillos and little cigars). Cigars that meet the definition of “premium cigars” in a court order (Cigar Association of America v. FDA 2023) as having only tobacco flavor would not be included because they do not contain characterizing flavor ingredients other than tobacco flavor. This proposed tobacco product standard, if finalized, could have a significant impact on reducing tobacco-related health disparities (Federal Register 2022b).

As sold, little cigars are often indistinguishable from cigarettes (Delnevo and Hrywna 2007). They resemble cigarettes in size and shape and are typically offered in packs of 20 (the minimum pack size for cigarettes in the United States), but they are defined as cigars because they are wrapped in a tobacco-containing wrapping paper (Table 3.5). Cigarillos are small cigars of varying sizes and may be offered in small packs of two or three. Although such products were available before the enactment of the Tobacco Control Act, sales of cigarillos and little cigars have increased significantly since the passage of the Tobacco Control Act (Regan et al. 2012; Cantrell et al. 2013; Delnevo et al. 2017; Kuiper et al. 2018). Sales of flavored cigars increased by almost 50% from 2008 to 2017 (Delnevo et al. 2017). Black & Mild and Swisher Sweets—sold in what are described as two-packs and three-packs—dominate the market of machine-produced cigars, having garnered more than 60% market share as of 2017 (Delnevo et al. 2017). Flavored little cigars and cigarillos have higher odds of availability and of lower prices in neighborhoods with higher proportions of African American people (Cantrell et al. 2013). More exterior advertising for little cigars and cigarillos has also been found in stores in neighborhoods with higher proportions of 18- to 34-yearold African American residents and in neighborhoods with higher proportions of young adult residents of any race (Cantrell et al. 2013).

Flavors in cigarillos and little cigars contribute to their popularity among youth (USDHHS 2012; Cantrell et al. 2013; Kong et al. 2017), as 65% of U.S. middle and high school students who used cigars in 2021 reported flavored cigar use (Gentzke et al. 2022). Furthermore, cigars contribute significantly to racial and ethnic disparities in the use of combustible tobacco products. In 2021, non-Hispanic Black students reported higher prevalence of current combustible tobacco product use (5.2%) than non-Hispanic White or Hispanic students, and specifically, cigar use (3.1%) (Gentzke et al. 2022). Available evidence suggests that (a) levels of carcinogens may be higher in mainstream smoke from little cigars than in mainstream smoke from cigarettes, which may be attributable to differences in tobacco blends, storage time for the tobacco leaf before manufacture, and manufacturing processes (Hamad et al. 2017), and (b) smoke from flavored little cigars has similar cytotoxic effects as the smoke from nonflavored or tobacco-flavored little cigars (Ghosh et al. 2017).

Table 3.5 Features of cigarettes, cigars, and cigar subtypes

Product | Wrapper | Stick characteristics | Pack size (excludes local and state restrictions) | Allowable characterizing flavors, as of March 2024 (excludes local and state restrictions)
Cigarettes | Typically paper | - Typically filtered | - Not less than 20 (required) | Menthol and tobacco only
Cigars | Substance containing tobacco | - Can be large or small | - No minimum | Any flavor (except premium cigars)
Little cigars | Substance containing tobacco | - Typically filtered; - Similar to cigarettes in size and shape | - No minimum, often offered in packs of 20 | Any flavor
Cigarillos | Substance containing tobacco | - Small cigars of varying sizes; - May have a plastic tip | - No minimum, often sold in packs of two or three | Any flavor
Large cigars | Substance containing tobacco | - Large, often machine made | - No minimum; - Often sold individually | Any flavor
Premium cigars | Whole leaf tobacco (not reconstituted tobacco) | - Typically handmade; - Filler contains at least 50% natural, long-leaf tobacco; - Weigh at least 6 lbs per 1,000 sticks; - Do not have filters or tips | - No minimum; - Often sold individually | No characterizing flavor other than tobacco

Notes: Most cigarettes are wrapped in paper, but they can also be wrapped in any substance not containing tobacco. The term “cigarette” also includes any roll of tobacco wrapped in any substance containing tobacco which, because of its appearance, the type of tobacco used in the filler, or its packaging and labeling, is likely to be offered to, or purchased by, consumers as a cigarette wrapped in paper or in any substance not containing tobacco. For federal tax purposes, “small cigars” are defined as cigars that weigh 3 lbs or less per 1,000 cigars, and “large cigars” are defined as cigars that weigh more than 3 lbs per 1,000 cigars (U.S. Government Publishing Office 2011). The U.S. District Court for the District of Columbia has defined premium cigars as those that (1) are wrapped in whole tobacco leaf; (2) contain a 100-percent leaf tobacco binder; (3) contain at least 50-percent (of the filler by weight) long filler tobacco; (4) are handmade or hand rolled; (5) have no filter, nontobacco tip, or nontobacco mouthpiece; (6) do not have a characterizing flavor other than tobacco; (7) contain only tobacco, water, and vegetable gum with no other ingredients or additives; and (8) weigh more than 6 pounds per 1,000 units (Cigar Association of America v. FDA 2023). FDA = U.S. Food and Drug Administration.

The top selling brands of cigarillos and little cigars, such as Black & Mild and Swisher Sweets, are marketed in colorful and flavorful varieties. Fruit, candy, and alcohol flavors include cherry, cherry vanilla, wine, cocktail, apple, and cream. Jazz, sweet wood, casino, and wine flavors are commonly sold flavors by Black & Mild. Concept flavor names, such as Island Bash and purple, may imply a flavor, such as tropical fruit or grape, without explicitly naming the characterizing flavor. However, more ambiguous concept flavor names, such as jazz and casino, may describe an attractive environment that appeals to people with particular lifestyles, while the flavor implication is less clear.

Concept flavor names are common in cigars (Gammon et al. 2019; Birdsey et al. 2019) but are also used in other tobacco products, such as e-cigarettes, cigarettes, and smokeless tobacco. FDA considered concept flavor names in proposing the tobacco product standard prohibiting characterizing flavors other than tobacco in cigars (Federal Register 2022b).

For example, Box 3.3 lists some of the cigar concept flavor names from two brands that have the highest market share in the United States, Black & Mild and Swisher Sweets (Gammon et al. 2019; Delnevo et al. 2021b).

Box 3.3 Example concept flavor names by two brands of cigars: Black & Mild and Swisher Sweets

- Aromatic (Swisher Sweets)
- Blazing fire (Swisher Sweets)
- Casino (Black & Mild)
- Coastal cocktail (Swisher Sweets)
- Diamonds (Swisher Sweets)
- Island bash (Swisher Sweets)
- Jazz (Black & Mild)
- Purple swish (Swisher Sweets)
- Smooth (Swisher Sweets)
- Wild rush (Swisher Sweets)

Chemical analysis has revealed that the typical compositions of flavor chemicals in flavored cigarillos and little cigars are similar to the flavor chemical compositions in candy products. For example, in one comprehensive analytic study, a grape-flavored blunt cigar was found to contain methyl anthranilate, a typical component of grape-flavored candy (Brown et al. 2014). An apple-flavored cigarillo contained 1-hexanol, and cherry-flavored cigarillos and cigars contained benzaldehyde and benzyl alcohol, which are typical apple- and cherry-flavored chemicals found in candy, respectively (Brown et al. 2014). Raspberry-flavored products contained raspberry ketone, and many cherry-flavored cigarillos contained vanillin, the vanilla flavor (Brown et al. 2014). Benzyl alcohol, the cherry flavorant, was also found in peach-flavored and grape-flavored cigarillos, suggesting that the accuracy of the fruit flavors listed on packaging is limited and that it may be challenging for consumers to distinguish these flavors (Brown et al. 2014). Other frequently used flavorants include ethyl maltol (cotton candy flavorant) and linalool (a flowery and fruity flavorant). Many flavored cigarillos and little cigars contain varying amounts of menthol even though menthol may not be marketed as a characterizing flavor in the cigar (Brown et al. 2014).

Menthol flavored tobacco products are popular among youth and among Black or African American people who use tobacco products, and menthol is often marketed as a characterizing flavor in cigars (Sterling et al. 2016a; Cohn et al. 2017; Rose et al. 2020). Furthermore, among Black adults who smoked cigarettes, perceiving menthol additives in little cigars and cigarillos as less harmful compared to tobacco flavor was associated with statistically significantly higher odds of using flavored little cigars and cigarillos compared with those who perceived that menthol flavor additives were as harmful as tobacco flavor (Sterling et al. 2016a).

##### Clove Cigars

Following the prohibition of clove as a characterizing flavor in cigarettes mandated under the Tobacco Control Act, Kretek International began selling clove-flavored cigars under the Djarum brand (Delnevo and Hrywna 2015; Jo et al. 2015). The company increased the weight of the product to more than 3 pounds per thousand sticks, enabling classification as a cigar for tax purposes. Sales for this brand in the United States increased from $444,192 in 2009 to approximately $6.7 million in 2012 (Delnevo and Hrywna 2015).

##### Artificial Sweeteners in Cigarillos and Little Cigars

Many cigarillos and little cigars are designated as having a sweet flavor. After the 2009 enactment of the Tobacco Control Act, which prohibited all characterizing flavors except menthol and tobacco in cigarettes, the tobacco industry filed several applications for patents describing the design of novel cigarillo products. One application, filed by Altria (Philip Morris), the owner of the Black & Mild brand of cigarillos, described procedures to add artificial sweeteners to the tobacco wrapper and mouthpiece (Sweeney et al. 2013). Later, Erythropel and colleagues (2018) analyzed sweetener additives in cigarillos marketed as sweet in the United States and compared the products with cigarillos with other flavor designations; 31 cigarillos and little cigars were tested from six of the top-selling U.S. brands in 2016 (combined 89% market share) (Giovenco et al. 2018). All but two of the tested cigarillos contained high-intensity sweeteners on the side or tip of the mouthpiece (Erythropel et al. 2018). Saccharin and glycyrrhizin, derived from licorice, were detected most often. Levels of sweetness did not appear to differ in the cigarillo parts touching the mouth (the side or tip of the mouthpiece). In most cigarillos, the sweetener was restricted to the mouth section. The sweetener was found throughout the wrapping leaf in some cigarillos. Acesulfame K and neotame, two heat-sensitive sweeteners, were detected on wood-tipped cigarillos, resulting in very high levels of sweetness (Erythropel et al. 2018). Sweeteners were not found on cigarillos with plastic tips, but only a few cigarillo brands were sold with these tips (Erythropel et al. 2018). These findings suggest that high-intensity sweeteners are used in almost all cigarillos and little cigars marketed in the United States, regardless of the flavor designation.

The placement of sweeteners on the mouth end of tobacco products may trigger intense perceptions of sweet flavors. Sweet flavors may mask the otherwise harsh effects of tobacco and nicotine in cigarillos. Studies indicate that the preference for sweet flavors is higher among children and adolescents than it is among adults (Hoffman et al. 2016). Similar to the situation with U.S.-marketed snus (a form of smokeless tobacco), the sweetness of wrapping papers on cigarillos and little cigars is exceedingly intense compared with sucrose (Erythropel et al. 2018). The combination of intense sweetness and candy flavorings likely contributes to the appeal of cigarillos and little cigars among adolescents and young adults.

##### Disparities in the Use of Cigarillos and Little Cigars

The sales of little cigars have increased in the United States and have contributed to overall sales of cigars (Gammon et al. 2019; Wang et al. 2022a). As noted, cigarillos and little cigars marketed in the United States are popular among African American adolescents and young adults (Cantrell et al. 2013; Sterling et al. 2015, 2016c; Nasim et al. 2016). In addition, a small national study found that transgender adults had nearly four times higher odds of smoking cigars compared to cisgender populations (Buchting et al. 2017). Marketing tactics by the tobacco industry that likely contribute to these disparities in cigar use are discussed further in Chapter 5.

The Tobacco Control Act prohibits the sale of cigarettes in packages of fewer than 20 cigarettes. However, cigarillos and little cigars remain available in packages containing only two or three items, making such products more affordable and potentially more attractive to young people who are experimenting with these products (Ganz et al. 2021). Tobacco industry documents suggest that product design and flavoring was a deliberate and iterative process to optimize the appeal of cigarillos and little cigars to youth, women, and African American people who smoke, especially those who smoke mentholated tobacco products (Kostygina et al. 2016). Studies suggest that some African American people who smoke cigars hold inaccurate perceptions that (a) cigarillos and little cigars are less risky than cigarettes, citing their fruity or medicinal flavors, and (b) they consist of “natural” tobacco, suggesting that they are absent of additives and thereby less harmful. However, the scientific evidence does not support that these products are less harmful (NCI 1998; Chang et al. 2015). In contrast, some African American people who smoke perceive cigarettes to be industrial products with poor-quality tobacco and greater risk (Cornacchione et al. 2016; Sterling et al. 2016b,c).

People who use cigarillos and little cigars often use multiple tobacco products, also known as polytobacco use or polyuse (Lee et al. 2014; Sterling et al. 2016a; Cheng et al. 2017; Roberts et al. 2017). In an online survey of U.S. adults 18–44 years of age who smoked cigarettes, about 45% of the young adults sampled (18–24 years of age) reported also smoking little cigars and cigarillos, and 55% of the young adults smoked cigarettes only (Sterling et al. 2016c). Some African American males who smoked menthol cigarettes used cigarettes and cigarillos or little cigars interchangeably and preferred menthol notes (i.e., that menthol could be one of many added flavorants) in cigarillos (Sterling et al. 2016a).

Another use for cigarillos and little cigars is to produce blunts, whereby the tobacco filling is partly or completely replaced with cannabis (Giovenco et al. 2017). Approximately two-thirds of adolescents who currently use cigars report using cigars to make blunts (Trapl et al. 2018). Focus groups of adolescents and young adults revealed that flavors, low prices, availability and accessibility (including ability to bypass age restrictions), and easily opened perforated wrappers made cigars useful for blunt use (Kong et al. 2018).

#### Smokeless Tobacco Products

Smokeless tobacco products—including chewing tobacco, moist snuff, and snus—are available in a wide range of characterizing flavors in the United States, and the tobacco industry has frequently introduced novel flavor combinations. The flavor chemical compositions in smokeless tobacco products are often similar to the flavors in confectionary products, such as hard candy, mints, and chewing gum (Chen et al. 2010; Brown et al. 2014). For example, benzyl alcohol has been identified as an added flavor in cherry candies and cherry-flavored tobacco products (Brown et al. 2014). Several studies have shown that the chemical concentrations of flavors in smokeless products are significantly higher than such concentrations in confectionary products (Chen et al. 2010; Miao et al. 2016).

##### Menthol and Methyl Salicylate Flavors in Smokeless Tobacco Products

Mint and wintergreen flavors are the most popular flavors among people who use smokeless tobacco products in the United States (Chen et al. 2010; Brown et al. 2014; Bonhomme et al. 2016). Mentholated smokeless tobacco products marketed in the United States often contain high levels of menthol. In a 2010 study, the average level of menthol per gram (g) of smokeless tobacco was 4.3 milligrams (mg/g), and the highest level was 5.3 mg/g (Chen et al. 2010). These levels exceeded the menthol contents in confectionary products at that time, which ranged from 2.1 to 3.5 mg/g (Burdock and Fenaroli 2010; Chen et al. 2010).

Smokeless tobacco products often contain high levels of methyl salicylate, the wintergreen flavor, relative to the acceptable daily intake (ADI) of methyl salicylate of 0.5 mg/kg per day specified by the Food and Agriculture Organization of the United Nations and the World Health Organization (Chen et al. 2010; Lisko et al. 2014). In 2010, the average level of methyl salicylate in smokeless tobacco products marketed in the United States was 23.8 mg/g; the highest level measured was 29.7 mg/g. These levels were 5 to 15 times higher than the level of methyl salicylate found in confectionary products and hard candy, which ranged from 2.0 to 4.6 mg/g (Burdock and Fenaroli 2010; Chen et al. 2010). These findings raise concerns that people who regularly use smokeless tobacco products may exceed the ADI of methyl salicylate (Chen et al. 2010; Lisko et al. 2014). Additionally, methyl salicylate ingestion can be fatal at high levels (Chan 1996; Mount Sinai–New York n.d.).

##### Artificial Sweeteners in Smokeless Tobacco Products

Tobacco industry documents list various sweeteners that have been used in some smokeless tobacco products, but new sweeteners and product categories have since been introduced (Wang 1993; FDA 2018a). Miao and colleagues (2016), in their analysis of sweeteners used in smokeless tobacco products marketed in the United States, revealed that these products contain only trace amounts of added natural sugars (<0.08% weight/weight). Among U.S.-marketed moist snuff products tested by Miao and colleagues (2016), all contained saccharine, and just one contained sucralose. Among snus products, sucralose was detected at high levels in all of the products examined; each pouch of snus contained 6–11 mg of sucralose. Snus pouch wrapping materials also contained sucralose, and a subset of snus products contained aspartame. The study also examined a dissolvable tobacco product that has since been discontinued. This product contained sorbitol—a sugar alcohol with a sweetness comparable to that of sucrose. Sorbitol accounted for more than 50% of the bulk of the product—but also contained a high amount of sucralose (4.48 mg/unit) but no aspartame or saccharine. The amount of sucralose in the examined dissolvable product was higher than the amount of sucralose in confectionary products. The majority of the moist snuff products sold in the United States were introduced before sucralose was approved for use in foods in 1999 (FDA 2018a).

Saccharin is perceived as sweet but also has a bitter taste. Due to their favorable properties, including lack of bitterness, sucralose and aspartame replaced saccharin as a high-intensity sweetener in most food products (Bartoshuk 1979). Tobacco manufacturers may not have replaced saccharin in snuff products because people who have used them long term have been habituated to its taste profile and may disapprove of a change to other sweeteners. This view is supported by the observation that the saccharin content in snuff products marketed in 2016 (Miao et al. 2016) did not differ much from the levels in snuff products measured in the early 1990s (Wang 1993).

In contrast to moist snuff, all snus products marketed in the United States contain sucralose, mostly in combination with aspartame (Miao et al. 2016). Snus products were introduced in the U.S. market in 2006 when sucralose was already widely used in food products (Biener and Bogen 2009). According to Miao and colleagues (2016), the levels of sucralose in the tests of U.S.-marketed snus products, both by percentage of weight and weight per product unit, exceeded the levels of sucralose in any solid confectionary product (candy, mint lozenges, chewing gum). The levels of sucralose per snus pouch (6–11 mg/unit) were much higher than the levels of sucralose in confectionary products (<0.4 mg/unit). Thus, absolute levels of sucralose in snus were 14 to 25 times higher than the highest levels of sucralose in any candy product (Miao et al. 2016). Levels of saccharin were higher in moist tobacco products than they were in snus, gum, sugar-free candy, soda, e-cigarettes, and dissolvable tobacco products. Snus contained higher levels of aspartame than the aforementioned products, indicating that the types and amount of sweeteners vary by tobacco product and can exceed levels found in nontobacco products (Miao et al. 2016).

These data show that smokeless tobacco products are likely to be more highly sweetened than confectionary products. With sucralose perceived as 600 times sweeter than sugar and with added aspartame, the sweetness of snus and dissolvable tobacco products exceeds the sweetness of their unit (pouch or lozenge) weight in sugar (Miao et al. 2016; FDA 2018a). For example, a Camel Snus pouch with 6–7 mg of sucralose per pouch is as sweet as 3.6–4.2 g of sugar. The sweetness of a Camel Snus pouch that weighs only 0.55 g is seven to eight times as intense as the sweetness of a piece of sugar with the same weight (Miao et al. 2016).

Intense sweeteners may be used to mask the adverse taste and sensory effects of the processed tobacco in smokeless tobacco products, which contains irritating and bitter nicotine and other tobacco constituents (Kroeze and Bartoshuk 1985). The optimal levels of sweetener in smokeless tobacco products are likely determined in tests by internal company panelists and consumer groups, suggesting that higher levels of sweetness are required to establish the palatability of these tobacco-containing products (Cantrell and Morgan 2006; Cantrell and Brown 2009).

Research by the tobacco industry revealed that the average male who uses snus consumes 12 pouches per day (Krautter et al. 2015; Cheng et al. 2017). Thus, with one snus pouch delivering as much as 11 mg of sucralose, the average male who used snus would consume as much as 132 mg of sucralose per day. Although this amount is still below the ADI of 5 mg per kilogram of body weight per day (FDA 2018a), consumption of additional sucralose-containing products—such as beverages, candy, and baked goods—may lead people who use snus to exceed the ADI for sucralose. Notably, a study by Pepino (2015) revealed that non-nutritive sweeteners affect metabolic signaling in pancreatic beta cells and change the composition of the gut microbiome, potentially contributing to metabolic dysregulation.

##### Disparities in the Use of Smokeless Tobacco

Among U.S. adults overall, the prevalence of smokeless tobacco use was 2.3% in 2020. However, the prevalence of smokeless tobacco use is higher among American Indian and Alaska Native adults (6.8%) than among Asian (0.4%), Black (0.8%), Hispanic (0.4%), and White (3.2%) adults; higher among people living in rural locations (5.9%) than among those living in urban locations (1.7%); and higher among male adults (4.5%) than among female adults (0.3%) (Cornelius et al. 2022). The use of smokeless tobacco is especially high in rural areas in the southeastern and southern United States, driven in part by targeted tobacco industry marketing to these communities (see Chapter 5) (Bell et al. 2000; Arabi 2007; Talley et al. 2011; Miller Lo et al. 2017; Pesko and Robarts 2017; Roberts et al. 2017). It is unclear whether the flavor profiles of marketed smokeless products contribute to or simply maintain the disparities in use patterns.

##### Trends in Smokeless Tobacco Sales

Sales of smokeless tobacco products in the United States have increased from $2.94 billion in 2011 (122.7 million pounds) to $4.82 billion in 2020 (126.9 million pounds)^2^ (Federal Trade Commission 2021). Smokeless tobacco products that are offered in pouches, such as moist snuff and snus, are increasingly popular and may appeal to new users who do not like the aversively strong taste of loose smokeless tobacco products and who have the perception that loose smokeless tobacco products are “unclean” (Delnevo et al. 2014). The smokeless tobacco market is also partially driven by value or discounted brands such as Grizzly, which accounted for 33% of the market in 2019 (Delnevo et al. 2021a).

Together, loose and pouched moist snuff products dominate the U.S. smokeless tobacco market. However, when the tobacco industry introduced snus products in the United States, it marketed these products as “reduced risk alternative” products (basing its argument on the reduced content of tobacco nitrosamines in snus compared with that in cigarettes) (Stepanov et al. 2008). In 2019, FDA authorized Swedish Match USA to market eight snus products with the modified risk claim, “Using General Snus instead of cigarettes puts you at a lower risk of mouth cancer, heart disease, lung cancer, stroke, emphysema, and chronic bronchitis” (FDA 2019). Since 2006, snus products have been marketed with larger pouch sizes and, in more recent years, with more flavor choices (Stepanov et al. 2012). For example, the marketing for Camel Snus Mellow may suggest a mild flavor to consumers and may appeal to new users who find other taste choices to be too strong (Minaker et al. 2014). In general, however, the uptake of snus continues to be low in the United States, despite some recent sales growth (Biener et al. 2016; Federal Trade Commission 2021). From 2019 to 2020, sales of snus increased from more than $169 million to $179 million, and sales of the much larger moist snuff category increased from $4.07 billion to $4.35 billion^3^ (Federal Trade Commission 2021).

#### Nicotine Pouches

Nicotine pouches were introduced in the United States in 2016 (Marynak et al. 2021). These products contain either tobacco-derived or nontobacco (e.g., synthetic) nicotine without tobacco leaf material, as well as flavorants and sweeteners in a microfiber pouch. The pouches are inserted behind the upper lip, similar to snus. Sales of nicotine pouch products grew rapidly in the United States with nearly 46 million units sold from January to June 2020 (Marynak et al. 2021). Growth has continued since, with Swedish Match’s ZYN brand leading sales with more than 200 million units sold and 66.5% of market share in 2022 (Swedish Match 2022). Nicotine pouch products, including ZYN brand, are sold in several nicotine levels; contain sweeteners, including sucralose and acesulfame potassium (an artificial sweetener also known as Ace-K); and are offered in a wide variety of flavors, including menthol, mint, wintergreen, citrus, cherry, cinnamon, and coffee (Marynak et al. 2021). Varieties of the ZYN brand, such as smooth and chill, have been advertised as “flavor ban approved” (Tackett et al. 2022; Jabba et al. 2023), and a chemical analysis study revealed that ZYN Chill contains the synthetic cooling agent, WS-3, which produces cooling sensations that are a key component of flavor experiences (Jabba et al. 2023). Moreover, ZYN Chill is described on the U.S. version of the ZYN website as “a refreshing unflavored nicotine experience” (ZYN n.d.) (Figure 3.10), with one online reviewer saying the product “has a slight sweetness” and observing that ZYN Chill variety has “an actual chilling sensation which is honestly refreshing” (Tackett et al. 2022). Marketing products as “unflavored,” despite apparently discernable somatosensory properties (e.g., refreshing, chilling), illustrates the importance for any tobacco product standards to explicitly include somatosensory aspects of flavor without discernable taste or smell.

Figure 3.10 Cooling varieties, including the concept flavor name, Chill, for the nicotine pouch brand, ZYN

Notes: Image depicts an email sent in May 2021 that announced the nationwide release of chill and menthol varieties of ZYN brand nicotine pouches. The chill variety is described as unflavored.

Email designed to promote consumers’ interests in ZYN brand nicotine pouches. Promotional text reads, “Now available nationwide. Chill and menthol. Whether you’re looking for something unflavored like chill or minty like menthol, these ZYN varieties bring the same level of discreet nicotine satisfaction that you know and love.” Additional text promotes the ZYN rewards program. The email also includes a warning label about nicotine.

Source: Trinkets & Trash (2021).

Population-level studies, such as NYTS and PATH, are only beginning to survey the use of nicotine pouch products. For example, in 2021, an estimated half a million U.S. middle and high school students reported ever using nicotine pouches; among U.S. middle and high school students who reported use of nicotine pouches during the past 30 days, 61.6% reported using flavored nicotine pouches (Gentzke et al. 2022). In 2022, among high school students, reliable estimates of nicotine pouch use in the past 30 days were available only for non-Hispanic White (2.0%; 95% CI, 1.4–2.9) and Hispanic (1.1%; 95% CI, 0.7–1.8) youth. Although estimates of current nicotine pouch use were similar among these population groups, the prevalence of ever use of nicotine pouches was higher among non-Hispanic White youth (4.8%; 95% CI, 3.5–6.5) than it was among Hispanic youth (1.4%; 95% CI, 1.0–2.1) (Park-Lee et al. 2022). Additional nationally representative data are needed to determine whether flavored nicotine pouch products—or other emerging oral nicotine products such as nicotine lozenges, nicotine tablets, or nicotine toothpicks—contribute to youth initiation of tobacco products and/or tobacco-related health disparities.

#### E-Cigarettes

This section describes chemicals and flavorants added to e-cigarettes to impart cooling and sweetness.

##### Cooling Flavors and Synthetic Cooling Agents in E-Cigarettes

Cooling flavors, including but not limited to menthol, represent a large segment of the e-cigarette market. Descriptors for cooling flavors may include menthol, ice, cool, chill, freeze, and frost and may be combined with fruity flavors (e.g., banana ice) or concept flavor names (e.g., lush ice) (Ali et al. 2022). From January 2017 to November 2021, unit sales of cooling flavored e-cigarettes increased by 693.0%, and the share of cooling flavors among total e-cigarette unit sales increased from 26.4% to 54.9% (Ali et al. 2022). During the same period, the percentage of e-cigarette menthol sales as a proportion of cooling flavors decreased from 94.5% to 73.0% (Ali et al. 2022).

Synthetic cooling agents for use in e-liquids are widely available to the public for purchase from online suppliers in the United States and elsewhere (Jabba et al. 2022). In addition, many flavored e-liquids are advertised to contain cooling agents, often using the general name Koolada. Available agents are WS-3, WS-5, WS-23, and L menthyl lactate (Table 3.4). As described in Table 3.4, WS-3 and WS-5 are synthetic chemicals and are nearly odorless and tasteless. According to one manufacturer (Symrise n.d.), WS-3 has cooling properties that impact the back of the mouth and tongue and the roof of the mouth, whereas WS-5 has cooling effects on the roof of the mouth and back of the tongue. WS-5 has a bitter after-taste and is one of the strongest coolants, with more than twice the intensity of WS-3 (Symrise n.d.). These odorless synthetic coolants may be used by the industry as a potential strategy to circumvent characterizing flavor restrictions (Jabba et al. 2022), including for combustible menthol cigarettes.

Analytic studies by the tobacco industry revealed the presence of WS-3, L-methyl lactate, and menthoneglycerol-ketal in e-cigarette aerosol (Moldoveanu and Kilby 2014). An independent study also found synthetic coolants in e-liquid refills and in the disposable e-cigarette brand Puff Bar, including in fruit-, dessert-, and sweet-flavored products (Jabba et al. 2022). Notably, the study found that e-cigarette products marketed in the United States can contain WS-3 and WS-23, and “carryover of [these] synthetic cooling agents from e-liquids into the vapor was highly efficient, approximating 100%” (Jabba et al. 2022, p. 1042). For most of these (18 of 25 refill liquids analyzed and 10 of 14 Puff Bars analyzed), modeling the long-term daily consumption of the vaped e-liquids suggests that consumer exposures could exceed safety thresholds for organ toxicity established by the Joint Expert Committee on Food Additives, which is jointly administered by the Food and Agriculture Organization of the United Nations and the World Health Organization (Jabba et al. 2022).^4^ Additional research into the presence and health effects of synthetic cooling agents in all tobacco products is warranted.

##### The Sweet Taste of E-Cigarettes: Learned Conditioning and Sweeteners in E-Liquids

Many sweet and fruit flavored e-cigarettes are advertised and marketed. Content analyses of advertising on e-liquid bottles and websites indicate that pictorial images that depict different flavors (e.g., apple pie, chocolate) are used to promote sweet and fruit-flavored e-liquids (Soule et al. 2019; Hardie et al. 2022). People who use these e-cigarettes often report that they perceive them as sweet flavored. Chemical analytic studies (n = 66) detected the presence of sugars (sucrose, glucose, or fructose) in a variety of flavored and unheated e-liquids, ranging from 6.4–88.9 μg/mL for glucose, to 8.8–331.2 μg/mL for fructose, and to 9.3–620.1 μg/mL for sucrose. Glucose was identified in 22% of samples, and fructose and sucrose were found in 53% of all samples (Fagan et al. 2018). This same study found a significant negative correlation between acrolein and fructose (r = −0.26, p = .0006), acrolein and sucrose (r = −0.21, p = .0006), formaldehyde and fructose (r = −0.22, p = .004), and formaldehyde and sucrose (r = −0.25, p = .002) (Fagan et al. 2018). Both acrolein and formaldehyde are listed on FDA’s list of harmful and potentially harmful constituents (HPHCs) in tobacco products (FDA 2012). Although all samples in this study were flavored, Fagan and colleagues (2018) did not test whether these concentrations elicited the perception of sweetness from people who use e-cigarettes.

The perception of sweetness of e-cigarette aerosol is likely derived, in part, from the solvents glycerol and propylene glycol. Glycerol, a sugar alcohol, is perceived as sweet but with an intensity lower than that of sucrose (i.e., table sugar) (Moskowitz 1971). Tests in young adults demonstrated that mixtures of glycerol and propylene glycol in water are perceived as sweet and that perceived sweetness increases with the concentration of glycerol and propylene glycol (Rao et al. 2018).

Sucralose is often found in e-liquids (Moser et al. 2021) and is widely available in vape stores and from online vaping supply stores for people to add to custom e-liquids (see, for example, EC Blend n.d.; Flavor Jungle n.d.; TBD Liquids n.d.). As a chlorinated derivative of sucrose, sucralose is much more heat-stable than other synthetic sweeteners and is considered safe for baking (FDA 2018a). However, as discussed previously, the safety of synthetic sweeteners when inhaled from tobacco products is unknown. For example, when sucralose is heated on metal surfaces, chlorinated organic chemicals have been reported to decompose and/or form, which may catalyze the decomposition of the sweetener (Rahn and Yaylayan 2010; de Oliveira et al. 2015; Lu et al. 2015). Although sucralose is more heat stable than other synthetic sweeteners, an analytic chemical study revealed that sucralose is unstable when aerosolized by e-cigarettes, producing toxic chlorinated organic compounds (Duell et al. 2019). In online message boards about vaping, people who use e-cigarettes often report sucralose deposits on the coil, suggesting that significant amounts of the sweeteners are not aerosolized and may be concentrated on and near the coil, raising concerns about thermal decomposition and the generation of toxic products (Dong et al. 2013; Lu et al. 2015). In a study by Rosbrook and colleagues (2017), participants comparing flavored e-cigarettes with and without sucralose could only discern the presence of sucralose when using cartridge systems, which is likely due to a higher concentration of sucralose in the aerosol from cartridge systems compared with the concentration in the aerosol from tank systems. This study suggests that e-cigarette delivery systems may result in highly variable aerosol yield and deposits of sucralose in the mouths of people who use e-cigarettes (Rosbrook et al. 2017).

Ethyl maltol, used as a sweet flavorant, is widely used by the e-cigarette industry and is known as the cotton candy flavorant (Tierney et al. 2016). Erythritol, a sugar alcohol, is another compound offered as a sweetener by online vape stores (Nude Nicotine n.d.). Erythritol has cooling effects, is structurally related to glycerol, and is 60–70% less sweet than sucrose (BeMiller 2018). It is unclear if erythritol imparts a significant sweetness (BeMiller 2018).

Some online suppliers of e-liquids also offer stevia sweeteners, which contain stevioside. Studies have not explored how frequently people who use e-cigarettes have customized their e-liquids with stevia sweeteners. Similar to sucralose, there is no information on the safety of stevioside when inhaled through the use of tobacco products.

## The Physiology of Flavor Perception

Menthol cigarettes are an important focus of scientific and public health efforts because (1) since September 2009, federal law prohibits the sale of cigarettes in the United States with characterizing flavors other than menthol (and tobacco) and (2) menthol cigarettes are disproportionately used by certain population groups, such as African American and Native Hawaiian people, youth, young adults, women, members of minoritized sexual orientation and gender identity groups, and people with lower incomes (Chapter 2, Table 2.6) (Cubbin et al. 2010; Rock et al. 2010; Jones et al. 2013; Giovino et al. 2015; Villanti et al. 2016).

As indicated in the introduction, flavor is a combination of retronasal olfactory sensations, somatosensory perceptions, and taste, with the latter including the ability to experience sweet, salty, sour, bitter, and umami tastes (Wolfe et al. 2014). In essence, flavor chemicals are chemicals that can be added or created through chemical processes and impart the senses of taste (gustation) and smell (olfaction), contributing to flavor experiences. Not everyone experiences taste and smell the same way. In addition to such factors as marketing, physiological factors and genetics can influence how different racial and ethnic groups, women, and youth experience flavors.

In context with targeted marketing tactics by the tobacco industry (discussed in Chapter 5), knowing how flavor perceptions, including perceptions of menthol, could be manipulated to influence the use of tobacco products by members of these groups, is critical to understand tobacco-related health disparities. Appendix 3.1 provides a foundation for understanding the underlying mechanisms and physiology of flavor perceptions, including how olfaction (sense of smell), gustation (sense of taste), and activation of the somatosensory system can influence tobacco use behaviors.

### Disparities in the Physiology of Flavor Perceptions

As discussed previously, taste is one component of flavor. Tobacco use changes the size, shape, and vascularization of the tongue’s papillae (Pavlos et al. 2009), thus elevating taste thresholds and leading to a loss of taste overall (Tomassini et al. 2007; Khan et al. 2016). Humans distinguish five basic taste qualities: sweet, bitter, sour, salty, and umami. Umami is the savory taste of amino acids and nucleotides, such as glutamate, that are used as taste enhancers. These five basic taste qualities invoke multisensory experiences for people who use tobacco products. Sweet, salty, bitter, sour, and umami tastes appear to decrease with age, and on average, women perceive tastes more intensely than men (Hoffman et al. 2016; Barragán et al. 2018). A review study found that youth have a greater preference for sweet flavors than adults, and that both sweet preference and aversion to bitterness decline as people age (Hoffman et al. 2016). Additionally, not everyone experiences the five basic tastes in the same way because of genetic variability in taste-specific genes. For example, studies have found differences in bitter taste experiences by age, gender, and race and ethnicity (Mennella et al. 2005; Mangold et al. 2008), which in turn, may influence tobacco product use behaviors. Individuals who are better able to taste bitter compounds, such as the taste compounds present in tobacco smoke, may be less likely to smoke combustible tobacco products (Mangold et al. 2008; Risso et al. 2016a).

Additionally, a study found that people who use chewing tobacco had significantly lower taste perceptions for salty tastes—measured as average time to identify tastes—than those who did not use chewing tobacco (Kale et al. 2019). People who used chewing tobacco tended to have lower taste perceptions for sweet tastes and higher taste perceptions for sour and bitter tastes compared with people who did not use chewing tobacco; however, these differences were not statistically significant (Kale et al. 2019).

These factors can also influence whether and how people perceive the taste of nicotine, coolants, and chemical flavors. Some of these differences in taste perceptions are discussed in this chapter. These differences in taste perceptions, in combination with targeted marketing by tobacco companies, may help to explain the greater prevalence of flavored tobacco use in youth and young adults versus older adults (Dai and Hao 2019; Gentzke et al. 2022) and in people who are female versus people who are male (Rath et al. 2016; Pang et al. 2020; Gentzke et al. 2022).

Bitter perception is thought to have developed as a mechanism to avoid toxic chemicals in food, especially from certain toxic plants (Wooding 2006). Plant toxins—such as strychnine and ricin—are extremely bitter, and evolutionary mechanisms may have selected for traits that detect such toxins and signal intense bitter perception to produce avoidance behavior.

Menthol has irritating effects and can be perceived as bitter, resulting in some people who smoke choosing to use nonmenthol cigarettes. For example, although large percentages of different population groups who smoke use menthol (e.g., women, certain racial and ethnic and sexual orientation and gender identity groups), about 60% of the total population of adults who smoke do not use menthol cigarettes (see Table 2.6 in Chapter 2). Menthol can reduce irritation caused by tobacco irritants, such as acetic acid and cyclohexanone (Willis et al. 2011); however, menthol use at high levels can cause irritation. Data from the National Health and Nutrition Examination Survey showed that people who smoked menthol cigarettes reported greater bitterness due to 6-n-propylthiouracil (PROP) than those who smoked nonmenthol cigarettes (Duffy et al. 2019).

Individual differences in bitter perception of certain chemicals were first reported in a study by Fox (1932), in which phenylthiocarbamide (PTC) was perceived as extremely bitter by some test participants but not by others. This difference was subsequently identified as a heritable Mendelian trait, suggesting that genetic variations determine differences in taste perception (Snyder 1931; Wooding 2006). Studies in the 1960s revealed that detection thresholds for two bitter agents, quinine and 6N-PROP, a bitter agent detected by the same pathway as PTC, were higher in people who smoked than in people who did not smoke and were elevated in men who smoked heavily (Fischer et al. 1963; Kaplan et al. 1964). Several later studies corroborated this finding in people who smoked and were from various racial and ethnic groups. For example, a study in an American Indian population revealed that PTC non-taster status was strongly associated with cigarette smoking, including light smoking, compared with no smoking or social smoking (Enoch et al. 2001). Another study found that non-taster status was strongly associated with measures of nicotine dependence among a sample of African American adults who smoked, particularly among African American women who smoked (Mangold et al. 2008). These studies hypothesized that non-tasters are less averse to the bitter taste of cigarette smoke and are, therefore, at increased risk for nicotine addiction and heavy smoking (Enoch et al. 2001; Mangold et al. 2008; Risso et al. 2016a). A systematic review of studies on the preferences of consumers of e-cigarettes found that adults tend to dislike e-cigarette flavors that elicit bitterness and harshness (Zare et al. 2018). The tobacco industry has conducted prior research on taste preferences (Philip Morris Records Collection 2010), which might inform marketing tactics.

Some study participants perceive menthol to be mildly bitter when applied to their tongues (Green and Schullery 2003). A patent application by the company Givaudan described the discovery of TAS2R7, a menthol-activated bitter receptor, and proposed to use this receptor as a target to suppress the bitter taste of menthol that some consumers may perceive to be aversive (Slack and Pennimpede 2013).

### Contributions of Individual Systems and Targets to Flavor Perception

#### The Flavor of Tobacco Smoke

Tobacco smoke consists of many chemicals. The gas phase of tobacco smoke contains aldehydes—such as acrolein, croton aldehyde, and formaldehyde—that are irritants that trigger burning and itching sensations and activate the cough reflex (Lee et al. 2010; USDHHS 2010). Tobacco smoke also contains particulates, often covered with charged and reactive chemical moieties. Tobacco alkaloids may contribute to the bitter taste perception that is triggered by smoke inhalation and when using smokeless tobacco products (Lee et al. 2010). Tobacco smoke is hot, and the hot temperature can cause pain and coughing. Temperatures measured in the combustion coal at the burning end of the tobacco rod can reach 900°C during a puff and fall to 400°C between puffs (Baker 1981).

Multiple olfactory, gustatory, and somatosensory receptor systems contribute to generally aversive perceptions of tobacco smoke, especially in people who do not smoke or are just beginning to smoke. Transient receptor potential ankyrin 1 (TRPA1), the receptor of reactive irritants from smoke, is the primary receptor for smoke aldehydes in airway-innervating somatosensory neurons, and TRP vanilloid 1 (TRPV1), as a heat sensor, may respond to heated smoke (Bautista et al. 2006; Andrè et al. 2008; Escalera et al. 2008).

#### The Role of Nicotinic Receptors

##### The Bitterness of Nicotine

Nicotine is included in FDA’s list of HPHCs in tobacco products (FDA 2012). Nicotinic acetylcholine receptors (nAChRs) are the major pharmacological targets of nicotine in the brain, mediating its psychoactive and addictive properties (Govind et al. 2009; Wittenberg et al. 2020). nAChRs are also expressed in ganglia of the autonomic nervous system, contributing to the effects of nicotine on the cardiovascular system (Vieira-Alves et al. 2020). Nicotine also contributes to the taste and flavor perception of tobacco products. Nicotine has a bitter taste that initiates aversive behavior in animals (Dahl et al. 1997; Scott et al. 1998; Oliveira-Maia et al. 2009). Experiments in mice revealed that nicotine elicits both dependent and independent taste responses of TRPM5, an ion channel responsible for the peripheral transduction of bitter tastes (Oliveira-Maia et al. 2009). This same study found that mecamylamine, an nAChR inhibitor, significantly reduces the aversive taste experiences of nicotine (Oliveira-Maia et al. 2009). Two additional studies showed that that nAChR subunit genes are expressed in taste cells in the tongues of rodents and humans, giving rise to functional receptors (Qian et al. 2018a, b). These cells also expressed TRPM5 and bitter taste receptors, suggesting that activation of nAChRs in these cells elicits a bitter taste.

##### Peripheral Nicotinic Receptors

Peripheral somatosensory neurons also express nAChRs. The highest expression is found in vagal sensory neurons innervating the lungs and lower airways (Kaelberer et al. 2020). These neurons sense irritants and trigger the cough reflex and other respiratory defensive reflexes. Hexamethonium, an inhibitor of nAChRs, when administered as an inhaled aerosol, stopped cigarette smoke-induced respiratory reflexes in dogs, suggesting that nicotine is a major mediator of the irritant effects of smoke (Lee and Morton 1986). Human study participants reported perceiving cigarette smoke with higher levels of nicotine content as being more irritating than smoke with lower levels of nicotine content (Lee et al. 1993). Nicotine elicited calcium influx through nicotinic receptor ion channels into cultured vagal sensory nerves, suggesting that nicotine can excite vagal neurons that transmit irritant and pain signals (Xu et al. 2007). Experiments in mice revealed that nicotine at higher concentrations in cigarette smoke or in smokeless tobacco products activates the release of CGRP, a pro-inflammatory neuropeptide, from tracheal sensory nerve endings. At lower concentrations, this activity could be inhibited by mecamylamine, the inhibitor of nAChRs. Only at higher concentrations of nicotine were TRPA1 and TRPV1-related mechanisms of CGRP release detected (Kichko et al. 2013). When tobacco smoke was separated into the nicotine-free gas phase and the nicotine-containing particulate phase, TRPA1 was identified as the major mediator of CGRP release in response to gas-phase exposure, and nAChRs were solely responsible for CGRP release in the particulate phase (Kichko et al. 2015). These studies demonstrated that, while TRPA1 and TRPV1 can be activated by nicotine, nAChRs are at least 200-fold more sensitive to nicotine and respond robustly to high concentrations of nicotine in tobacco products. The vagal sensory neurons innervating the airways were found to express a diverse group of nAChR subunits (Mao et al. 2006; Gu et al. 2008; Kaelberer et al. 2020). Taken together, nicotine has substantial effects on taste and irritant sensing and contributes to the flavor perception associated with tobacco products, with peripheral nAChRs as major transducers.

#### Sensing of Menthol in Tobacco: Peripheral and Central Mechanisms

Menthol facilitates the inhalation of tobacco smoke or the oral use of smokeless tobacco by suppressing the aversive sensations elicited by irritants and bitter flavorants in tobacco, thereby aiding in tobacco use initiation (FDA 2013). Menthol also affects, either directly or indirectly, the dopaminergic reward circuity engaged by nicotine, modulating smoking behavior and making it harder for people who smoke menthol cigarettes to quit successfully (FDA 2013). Finally, menthol, through its unique chemosensory properties, can serve as a cue associated with a nicotine reward (Rose and Behm 2004; Wang et al. 2014; Wickham 2020). Studies in rodent models have revealed the fundamental mechanisms involved in these three effects, emphasizing menthol’s pharmacological actions during tobacco use.

##### TRPM8 and TRPA1-Mediated Effects of Menthol in Rodent Models of Tobacco Use Initiation

TRP melastatin 8 (TRPM8) was identified as the somatosensory receptor for menthol in cold-sensing neurons. In models of pain, activation of these neurons, either by physical cooling or by menthol and related cooling compounds, has analgesic effects. The analgesic effects of menthol were not present in mice that were deficient in the TRPM8 gene (Dhaka et al. 2007; Liu et al. 2013).

Studies in rodents investigated whether menthol has similar analgesic or counterirritant effects in the respiratory system. The respiratory irritation response, a sensory nerve-dependent reflex, permits mice and rats to respond to irritant exposures by lowering their respiratory rates (Alarie 1966; Ulrich et al. 1972; Alarie et al. 1998; Morris et al. 1999; Morris et al. 2005). This response is elicited by activation of trigeminal nerves in the nasal passages of rodents. The capability of a given irritant to elicit this response is used to classify the severity of irritants according to their RD50 (i.e., exposure concentration producing a 50% respiratory rate decrease), as measured by barometric plethysmography. Tobacco smoke irritants—such as acrolein (an aldehyde)—potently suppress respiration in mice. However, this response can be prevented by pretreatment with capsaicin, a TRPV1 agonist known to desensitize trigeminal sensory nerves to irritants (Morris et al. 1999).

A study using barometric plethysmography in mice revealed that menthol, at concentrations present in the mainstream smoke of cigarettes, stopped the respiratory irritation effects of tobacco smoke irritants (Willis et al. 2011). Irritants examined in the study included acrolein, acetic acid (an acidic irritant), and cyclohexanone. Menthol did not counter the irritant effects of cigarette smoke in mice that were pretreated with an inhibitor of TRPM8, demonstrating that TRPM8 is essential for menthol to suppress irritation. This study also examined the effects of eucalyptol, a menthol-related cooling product naturally found in eucalyptus leaves that is often added to tobacco products. Eucalyptol also suppressed respiratory irritation by acrolein, suggesting that menthol and menthol-related cooling compounds have counterirritant effects. This study also revealed that menthol’s own irritant effects rely on TRPA1, since TRPA1-deficient mice failed to display respiratory irritation when exposed to menthol vapor (Willis et al. 2011).

A later study examined the effects of menthol on irritation caused by exposure to tobacco smoke in mice (Ha et al. 2015). This study demonstrated that menthol, at concentrations observed in mainstream cigarette smoke, efficiently suppresses irritation, resulting in a higher respiratory rate in the presence of tobacco smoke. Mice exposed to mentholated tobacco smoke had higher levels of cotinine in their blood than mice exposed to nonmentholated tobacco smoke, suggesting that menthol’s counterirritant effects may facilitate the uptake of nicotine (Ha et al. 2015). Both studies used mice naïve to tobacco smoke, modeling initiation of tobacco use in people who have never smoked (Willis et al. 2011; Ha et al. 2015).

Similar effects of menthol were observed in oral nicotine intake studies modeling oral tobacco product initiation, such as the use of smokeless tobacco products that are often strongly mentholated. Mice, given the choice between a nicotine solution with an aversive nicotine concentration or the same nicotine solution with menthol, strongly preferred using the mentholated solution (Fan et al. 2016). Menthol was added at a concentration similar to levels estimated to be present in the saliva of people who use smokeless tobacco products. In contrast, TRPM8-deficient mice showed aversion to the mentholated nicotine solution and preferred the nonmentholated solution. This observation suggests that the TRPM8-engaged analgesic circuitry also suppresses underlying irritant effects of menthol that are unmasked when TRPM8 is absent. The effects of menthol on the nicotine intake of mice were shown to be sex- and age-dependent and involve an alpha-7 nicotinic receptor mechanism (Bagdas et al. 2020). TRPA1 mediates oral aversive effects of menthol when used at high concentrations (Lemon et al. 2019).

Taken together, these rodent models of tobacco product initiation, either through inhalation or ingestion, strongly support a role for menthol as a counterirritant, allowing people who use tobacco products to overcome the aversive sensory effects of these products. The relevance of animal models to humans is discussed later.

##### Menthol as a Cue for Nicotine Uptake and Relapse

Studies in rodents provide strong evidence that menthol can act as a cue for conditioning and reinforcing nicotine uptake and relapse. In conditioning experiments in adolescent rats, an oral menthol cue elicited more frequent intravenous self-administration of nicotine in rats in the treatment group than in rats in the control group (Wang et al. 2014). Conditioning with menthol also caused increased drug-seeking behavior when nicotine was withheld. Similar behaviors were observed when mice were given cold water or WS-23, an odorless synthetic cooling agent and TRPM8 agonist. This study demonstrates that the oral cooling properties of menthol can serve as a cue for nicotine taking (Wang et al. 2014). Another study in which rats were trained to press a lever to self-administer nicotine intake, signaled by a sensory cue using injection of menthol, had similar outcomes, demonstrating that menthol injection is a strong cue to reinitiate nicotine use after stopping (i.e., relapse) (Harrison et al. 2017).

Flavors, such as menthol, are often paired with sweeteners used in candy, chocolate, and baked goods, leading to conditioning to expect a nutritive reward. A study by Palmatier and colleagues (2020) modeled the initial association of menthol with sweetness and then investigated the effects of prior pairing on the self-administration of nicotine in mice. The study revealed that prior conditioning to menthol or licorice with sucrose increased selfadministration of nicotine, especially low levels of nicotine, in mice.

Together, these studies demonstrate that menthol can act as a strong cue for nicotine uptake, through TRPM8-mediated mechanisms upon oral exposure and TRPM8-independent mechanisms after injection. Olfactory exposure paradigms, using menthol vapor and smoke from menthol cigarettes, may reveal whether menthol can also serve as a robust olfactory cue for people who use mentholated tobacco products.

Further, Rose and Behm (2004) conducted a study examining the effects of several pharmacological (nicotine skin patches and an nAChR antagonist) and behavioral (switching to denicotinized cigarettes or to cigarettes having different menthol flavor or to ventilated-filter cigarettes) treatments on the response to rewarding cigarette smoking cues in a study of 233 adults who smoked and were recruited for a quit smoking study. Respondents rated the rewarding effects of their usual brand of cigarettes to cigarettes with differing menthol content (menthol or nonmenthol) during a 2-week treatment phase. This study found that all pharmacological treatments reduced reward ratings for the respondents’ usual brand of cigarettes compared to the placebo. However, there was a significant interaction between usual brand (menthol vs. nonmenthol) and the effect of pharmacological treatment on reward cues. People using any active pharmacological treatment who usually smoked menthol cigarettes and were switched to nonmenthol cigarettes did not show a reduction in the reward rating of their usual (mentholated) cigarette over the treatment period, but people who usually smoked nonmenthol cigarettes and who were switched to menthol cigarettes did show a significant decline in their reward ratings of their usual (nonmentholated) cigarette. According to the authors, these findings highlight the importance of sensory cues in influencing the reward of smoking (Rose and Behm 2004).

##### Olfactory Receptors for Menthol-Like Compounds

Menthol and menthol-like compounds often have a minty odor that is associated with the fresh, cooling, and sometimes stinging sensations elicited by these compounds. Although the somatosensory receptors for menthol, TRPM8 and TRPA1, have been identified, it has been much more difficult to identify specific odorant receptors. Humans and rodents express hundreds, if not thousands, of odorant receptors that express poorly in the heterologous systems used for screening G-protein-coupled receptors (GPCRs; see Appendix 3.1) (Matsunami 2005; Krautwurst 2008). Krautwurst and colleagues (1998) identified an odorant receptor that responds to carvone, the minty flavorant in spearmint. However, odorant receptors for menthol, menthone, eucalyptol, and other mentholrelated compounds remain elusive. Odorant detection is highly complex, as several odorant receptors respond to an odorant at different concentrations. Modern high throughput mRNA trapping and sequencing approaches have enabled the in vivo identification of odorant receptors in rodents for selected odorants, such as acetophenone (Jiang et al. 2015; Hu and Matsunami 2018).

##### Menthol’s Effects on Nicotinic Receptors and Central Reward Mechanisms

As described previously, nicotinic receptors in peripheral sensory neurons mediate the majority of sensory irritant effects of nicotine at concentrations measured during the use of tobacco products. A study examining nicotine-activated currents in trigeminal neurons revealed that menthol had inhibitory effects on these currents, suggesting that menthol may act on nicotinic receptors (Hans et al. 2012). When expressing human alpha-4 beta-2 nAChRs in a heterologous expression system, the study concluded that menthol can act as an allosteric modulator of nicotinic receptors. This mechanism may contribute to menthol’s counterirritant effects of nicotine-induced irritation in peripheral sensory neurons. Menthol was also shown to interact with alpha-7 nicotinic receptors to increase intake. For example, mice with operative alpha-7 nicotinic receptors consumed more mentholated nicotine than nonmentholated nicotine compared with mice with inoperative alpha-7 nicotinic receptors (Ashoor et al. 2013).

Recent studies revealed that menthol modulates behavioral responses to nicotine associated with nicotine’s effects in the central nervous system. For example, menthol was shown to blunt nicotine’s psychostimulant activities leading to decreased motor behavior in mice (Fait et al. 2017). Menthol facilitated the dopamine-releasing effect of nicotine in the nucleus accumbens of rats, showing that menthol interacts with nicotine to activate the brain reward system (Zhang et al. 2018).

More evidence for the actions of menthol came from studies investigating menthol’s effects on nAChRs involved in the dopaminergic reward circuitry in the central nervous system (Henderson et al. 2016, 2018; Avelar et al. 2019; Bavan et al. 2019; Mulcahy et al. 2020). Menthol was shown to modulate nicotine-induced neuronal currents in mice, either by directly reducing current amplitude or by preventing receptor desensitization while activated by nicotine (Henderson et al. 2016). Menthol had direct effects on the firing frequency of dopaminergic neurons after stimulating the nicotinic receptors and reduced behavioral responses associated with nicotine reward. Menthol may affect the stoichiometry of acetylcholine receptors, changing nicotine’s long-term effects. Long-term treatment with menthol combined with nicotine in mice led to increased neural activity of dopamine neurons that was significantly higher than in mice that were treated with nicotine alone, implying that the combination of menthol and nicotine triggers a stronger rewarding effect than nicotine alone (Henderson et al. 2017). In studies of self-administration of e-cigarette aerosol in mice, menthol enhanced the rate of acquisition of self-administration behavior (Cooper et al. 2021). Proteomic studies of mice revealed that administration of menthol plus nicotine altered the expression levels of nicotinic receptor subunits and more than 200 other proteins in the hypothalamus (Mulcahy et al. 2020). These alterations occur at concentrations of nicotine that approximate concentrations likely present in the central nervous system of people who smoke.

Menthol was also shown to inhibit the metabolism of nicotine, thereby slowing degradation of nicotine in the body and extending its pharmacological effects (Benowitz et al. 2004). Effects of menthol were also described in epithelial tissues, where menthol was shown to facilitate nicotine permeation, an effect that may lead to a more rapid increase of blood nicotine levels in people who smoke or use oral smokeless tobacco products (Squier et al. 2010).

#### A Green Apple Flavorant Eliciting Reward Mechanisms and Modulating Nicotinic Receptors

Although research on tobacco flavorants has focused predominantly on menthol and menthol-related natural or synthetic additives, evidence is emerging that other additives may also exert pharmacological, behavioral, and toxicologic effects beyond their function as pleasant odorants. For example, farnesol and farnesene are flavorants used in green apple, an e-cigarette flavor that is especially popular among adolescents and young adults (Avelar et al. 2019; Cooper et al. 2020; Jackson et al. 2021). Farnesol was shown to produce reward behavior in male mice that were tested in the conditioned place preference assay, a commonly used assay to measure motivational effects of substances by assessing the amount of time an animal spends in an area that has been associated with a stimulus (Avelar et al. 2019). This effect may have resulted from an increased firing frequency of dopamine neurons in the ventral tegmental area that were recorded after farnesol was administered. Farnesol increased expression of alpha-6* nAChRs in male mice but not in female mice; alpha-6* nAChRs may play a specific role in the initiation of nicotine reward. Farnesene, another green apple and food flavor, also triggered reward behavior in both male and female mice. Farnesene was found to directly affect nicotinic receptor currents, activating currents with approximately 30% of nicotine’s efficacy. The presence of farnesene significantly increased nicotine’s potency to activate currents in neurons in the ventral tegmental area. This was likely due to a shift in certain nAChR subunit types, with alpha-4 beta-2 receptors expressed more highly (Cooper et al. 2020). In addition, mice upon exposure to certain green apple flavorants—including farnesene, hexyl acetate, methylbutyl acetate, and ethyl acetate—displayed enhanced rates of self-administration and reinforcement behaviors (Cooper et al. 2021). These results strengthen the evidence that some flavorants by themselves and flavored e-liquids without nicotine can promote reward-related behaviors. With combinations of more than 200 flavorants used in e-liquids (Krüsemann et al. 2021), a comprehensive and systematic research program is required to better understand their pharmacological and behavioral effects. In addition to menthol and green apple flavorants, other flavorants likely affect reward behavior, modulate aversion and irritation responses, target cardiovascular physiology, and interact otherwise with pharmacological targets that are critical for addiction behavior and health.

#### Relevance of Animal Models to Human Health

Overall, animal studies have strengthened concerns about the pharmacological effects of menthol as an additive in tobacco products and have provided detailed mechanistic insights into counterirritant and behavioral effects of menthol. TRP ion channels—including TRPM8, TRPA1, and nicotinic receptors—show a high degree of conservation between rodent models and humans. As such, menthol targets are localized to the same neuronal tissues and cell types in both rodents and humans. Human psychophysical studies have produced comparable outcomes, reporting cooling, analgesic, antitussive, and counterirritant effects of menthol. For example, in studies with human participants, repeated application of a mixture of L- and D-menthol to the oral mucosa desensitized the burning and stinging sensations elicited by menthol, while the cooling effect persisted (Cliff and Green 1994). Additionally, Perkins and colleagues (2017) asked people who smoked menthol cigarettes to discriminate between menthol cigarettes with extremely low levels of nicotine and test cigarettes with higher levels of nicotine. The study found that to distinguish menthol from a nonmenthol taste, the nicotine content needed to be higher for people who smoked menthol cigarettes (>80%, 16 mg/g) than for people who smoked nonmenthol cigarettes (11 mg/g, p <0.005) (Perkins et al. 2018). The finding could be explained by a direct inhibitory or desensitizing effect of menthol toward nicotinic receptors (Henderson et al. 2016, 2017, 2019; Perkins et al. 2018; Cooper and Henderson 2020; Mulcahy et al. 2020).

Uncertainties remain about (a) the concentrations of flavorants and other chemical additives in tobacco products reaching the brain of humans and in animal models, (b) the differential disposition and metabolism of flavorants and other chemical additives, and (c) the differential habituation and conditioning to certain flavorants and other chemical additives due to their presence in the human diet and consumer products. Advances in the design of animal models, such as self-administration models of aerosol from e-cigarettes, are beginning to model human behavior more closely.

## The Roles of Genes in Flavor Preferences Among Disparate Populations

This section examines the relevance of genetics to the use of flavored tobacco products. It discusses how the tobacco industry has played a role in genetic research and tobacco use, describes key issues related to the role of race and ancestry in genetics research, and presents research related to gene variations that are linked to flavored tobacco use. Of note, some of the genetic studies on the role of flavor preferences described in this section may be limited in that they have investigated candidate loci only in relatively small cohorts.

### The Role of the Tobacco Industry in Genetic Research of Nicotine Addiction and Flavor Preferences

Multilevel factors help to explain disparities in the use of flavored tobacco products, including menthol-flavored products. The tobacco industry’s decades-long targeted marketing of menthol cigarettes to specific groups is one such factor. Accumulating evidence suggests that genetics are an additional factor determining flavor preferences and the increased vulnerability of specific groups to targeted marketing of certain flavors.

The tobacco industry has long been aware of genetic factors influencing flavor preferences. Since the mid-twentieth century, the tobacco industry encouraged and funded the formation of academic research groups to investigate the genetic determinants of nicotine dependence and flavor preferences (Kaplan et al. 1964; Gundle et al. 2010). These efforts were coordinated by The Tobacco Industry Research Committee—later renamed The Council for Tobacco Research—which was founded by the major tobacco companies in the United States in 1953.

The Council for Tobacco Research embarked on a funding program to support research at academic institutions and private research entities, with the goal of creating scientific controversy about the causal relationships between smoking and smoking-induced diseases, such as lung cancer (Tobacco Industry Research Committee 1954; Brandt 2012). Genetic studies were funded to prove the “constitutional hypothesis” that “one or more genes affect a person’s risk for lung cancer, and that at least some of the same genes influence whether people become smokers” (Gundle et al. 2010, p. 105). The goal was to deflect blame from the industry, claiming that the genetic constitution of certain groups of people who smoke is responsible for their heightened risk of cancer, and that most people who smoke are “safe” smokers who do not develop cancer (Gundle et al. 2010).

The Tobacco Industry Research Committee also funded some of the earliest genetic studies that examined genetic links to flavor aversion and preferences. Links between genetic variations determining flavor preferences and smoking behavior were first reported in the 1960s, suggesting that specific manipulation of tobacco product flavor profiles may increase product uptake in populations in which genetic traits favoring the resulting flavor profiles are represented. A widely cited study published in 1964 that reported a genetic link between the capability to detect certain bitter chemicals and smoking status was funded by The Tobacco Industry Research Committee (Kaplan et al. 1964). A search in the Truth Tobacco Industry Document Library revealed that the lead investigator of this study, conducted in Cleveland, Ohio, applied for a research grant to The Tobacco Industry Research Committee in 1962 (Ferris and Kaplan 1962) and submitted research progress reports to the Committee in 1963 (Kaplan 1963).

The tobacco industry has conducted research for decades on taster types (R.J. Reynolds 1987) and taste experiences to inform the design and engineering of cigarettes and the marketing of flavors, cooling and refreshing effects, and sweet tastes to specific population groups. The industry has used flavor panels to evaluate the influence of flavors on people who use tobacco products and combined their knowledge of flavor preferences with research on the appeal of images and colors (such as blue and green to connotate cooling of menthol) (R.J. Reynolds 1987), which continue to be used in targeted marketing of flavored tobacco products.

### Issues of Race and Ancestry in Genetics Research

This section describes studies that identified genetic variations linked to preference for menthol or nonmenthol cigarettes in some population groups. Information discussed in this chapter suggests that genetic variation and physiological factors, such as taster status, may help to explain why menthol is marketed aggressively to certain population groups. As such, the higher use of menthol among groups with specific genetic variations would not likely occur in the absence of such marketing. This section explores the potential effects of gene variations on smoking behaviors and flavor preferences, but as noted previously in this chapter, there is greater genetic variance within versus between racial and ethnic population groups (Jorde and Wooding 2004; Mersha and Beck 2020).

The discipline of genetics research is currently reassessing the use of race categories to designate and separate study populations (Yudell et al. 2016; National Academies of Sciences, Engineering, and Medicine 2023). In the past, genetic studies often relied on self-identification of study participants as belonging to a racial group, an approach now known to lack scientific rigor (Duello et al. 2021). Earlier, the eugenics movement used pseudoscience to rank races according to their purported genetic fitness and intelligence, justifying racial discrimination and egregious human rights violations (National Human Genome Research Institute n.d.). However, only recently, modern genetic techniques based on the advances of the Human Genome Project and its successors, such as the 1000 Genomes Project, have enabled more accurate determinations of ancestry and admixture from other populations for each study participant at a level of detail that was previously unattainable (The International Genome Sample Resource n.d.). These advances have been accompanied by discussions in the field that call for the use of ancestral categories and the abandonment of unfounded racial categorization of study populations, due to a lack of rigor and the fluidity of the social construct of “race” over time (Yudell et al. 2016). The genetic studies discussed in this section, published over a range of decades, need to be assessed from the perspective of these rapidly changing concepts, advancing technologies, and increased understanding.

#### Potential Effects of Variations in TRP Genes on Perceptions of Tobacco and Menthol

The disparities in menthol preference among people from different racial and ethnic backgrounds may be partly explained by variations in TRP ion channel genes—specifically the genes encoding for TRPM8 and TRPA1, the menthol receptors in peripheral sensory neurons. These are candidate loci that, depending on haplotypes, may affect sensitivity to menthol. For example, mutations leading to reduced expression of TRPM8 in peripheral nerves may result in diminished cooling sensation and weaker analgesic and counterirritant effects of menthol, as shown in mice that lack expression of TRPM8 (Dhaka et al. 2007; Liu et al. 2013; Fan et al. 2016). Carriers of such a hypomorphic haplotype may prefer more strongly mentholated tobacco products to achieve the same cooling and counterirritant effects and sustain nicotine levels.

Genetic variations in the TRPA1 gene, encoding for the major smoke irritant receptor, may affect the irritant sensitivity of carriers. For example, a clinical study in test subjects exposed to diesel engine exhaust found that variations in the TRPA1 gene were associated with an increase in cough frequencies (Yoon et al. 2022). Diesel exhaust and tobacco smoke share major irritants, such as the TRPA1 activators, acrolein, and particulate matter. Thus, carriers of sensitizing TRPA1 gene variations may also display increased sensitivity to irritants in tobacco smoke—such as acrolein, particulates, or nicotine—lowering cough threshold and causing oral, nasal, or throat irritation. Carriers of such gene variations may use menthol cigarettes to suppress irritation more efficiently via the TRPM8-mediated cold or analgesic pathway.

TRP ion channels were initially identified as sensors for chemical and physical stimuli in pain-sensing nerves and nerves transmitting temperature signals (hot, cool). Genetic analysis of a Colombian family affected by a familial episodic pain syndrome identified a mutation in the TRPA1 gene (i.e., the menthol or irritant receptor) as the underlying cause (Kremeyer et al. 2010; Boukalova et al. 2014). Chemical stimuli activated the resulting missense mutant (N855S) much more strongly, and homozygous carriers showed increased chemical pain responses. In animal studies, Andrè and colleagues (2008) demonstrated that the increased chemical sensitivity of the TRPA1 mutant clearly translates to human physiology, resulting in heightened sensitivity of mutation carriers to painful chemical stimuli. Similar mutations may increase the sensitivity to smoke irritants or menthol among people who smoke.

Migraine is another condition known to be activated by chemical stimuli in some people. Both menthol receptors, TRPA1 and TRPM8, are expressed in nasal and dural trigeminal nerve fibers implicated in migraine pain (Huang et al. 2012; Benemei et al. 2014; Dussor et al. 2014; Ren et al. 2018). Several genomewide association studies have linked variations in the TRPM8 gene to migraine (Chasman et al. 2011, 2014; Freilinger et al. 2012; Ghosh et al. 2013; Fan et al. 2014; Dussor and Cao 2016).

Thus, certain variations in menthol receptor genes can impact profoundly the chemical sensitivity and irritant responsiveness of carriers. Genetic variations in TRP genes may also affect smoking behavior and menthol preference in diverse populations of people who smoke.

Uhl and colleagues (2011) identified a human genetic variation that may be linked to a preference for menthol cigarettes in people who smoke heavily (≥15 cigarettes smoked per day). Focusing on allelic variants in the TRPA1 gene and encoding for the menthol-sensitive smoke or irritant receptor, the study analyzed the DNA of 820 American people of European ancestry from North Carolina and Baltimore, Maryland, who had a desire to quit smoking and who were recruited for previous addiction genetics studies (Drgon et al. 2010; Rose et al. 2010). The sample included 122 female and 100 male adults who smoked heavily and preferred menthol cigarettes, 243 females and 276 male adults of similar age who smoked heavily and preferred nonmenthol cigarettes, and smaller groups of people who smoked lightly who preferred menthol or nonmenthol cigarettes. Sixty-eight known single nucleotide polymorphisms (SNPs) in the TRPA1 gene were genotyped, and of these, data from the 51 SNPs that displayed minor allele frequencies >0.05 in this study population were analyzed. Of the 51 SNPs analyzed in the cohort of people in the heavy smoking group, 11 SNPs fulfilled the statistical linkage criteria (p <0.05) for association with smoking menthol cigarettes. These 11 SNPs are inherited together, representing a haplotype. Although 10 of 11 SNPs in this haplotype are intronic, SNP rs13268757 in the first exon of the TRPA1 gene changes the amino acid sequence (missense SNP). Irrespective of smoking intensity (heavy or light), this SNP in the TRPA1 gene (SNP rs13268757) was associated with preference for menthol cigarettes. However, this association was not statistically significant among people in the light smoking group (<15 cigarettes per day), possibly due to lower statistical power to detect differences in this group. Uhl and colleagues (2011) also investigated the DNA of people in a different heavy smoking group (≥15 cigarettes smoked per day) surveyed in 2006, identifying six SNPs in the TRPA1 gene that were linked to preference for menthol cigarettes. By analyzing the database of short genetic variations (National Library of Medicine 2018), Uhl and colleagues (2011) found a higher frequency of SNP rs13268757 in populations of Asian or African descent and proposed to investigate the linkage to preference for menthol cigarettes in these populations in the future.

In the study conducted by Uhl and colleagues (2011), SNP rs13268757 in the TRPA1 gene was the only polymorphism that changed the sequence of the TRPA1 receptor, causing an arginine amino acid residue (R; genetically encoded by nucleotide triplet CGC) at Position 3 of the TRPA1 protein to change into a cysteine amino acid residue (C; genetically encoded by nucleotide triplet TGC), named as the R3C mutation. To examine the functional effects of this R3C mutation on activation by chemicals related to irritants in tobacco smoke, Deering-Rice and colleagues (2015) used fluorescent imaging of Ca2^+^-flux in HEK293 cells. All irritants tested elicited stronger (twice as high) functional responses in the R3C-variant when administered at the same concentrations. This observation suggests that the R3C mutation increases the sensitivity of TRPA1 to irritants, resulting in higher Ca^2+^-flux at the same agonist concentration.

This sequence variation, located in the extreme N-terminal of the protein, may also modify the surface expression of TRPA1 channels in the cells, potentially resulting in a larger number of channels that allow greater amounts of Ca^2+^-ions to permeate the cell membrane. At this time, it is not known whether the R3C variation also results in increased TRPA1 currents in human sensory neurons. It may be possible that the respiratory sensory nerves of people who smoke and are carrying the mutation would be excited at lower densities of smoke, and carriers would perceive cigarette smoke as very irritating and painful. For example, smoke from nonmentholated cigarettes could feel more noxious than smoke from mentholated cigarettes to carriers, who might then choose to smoke menthol cigarettes because menthol, through the activation of TRPM8, would suppress the increased irritation (Figure 3.11). Further investigation is warranted to elucidate these relationships.

Studies of rodents have shown that TRPA1 is essential for pulmonary inflammation and airway hyperreactivity in both allergic and chemically induced asthma (Caceres et al. 2009; Hox et al. 2013; Devos et al. 2016). Several studies have linked TRPA1 gene polymorphisms to childhood asthma (Kremeyer et al. 2010; Gallo et al. 2017). Intriguingly, homozygous carriers of the mutation for familial episodic pain syndrome in the TRPA1 gene experience difficulties in breathing during the painful episodes, suggesting that the effects of the gain-of-function mutation extend to the respiratory system (Kremeyer et al. 2010).

Figure 3.11 Human TRPA1 SNPs linked to disparities in menthol preference, asthma, and pain syndromes

Notes: The R3C polymorphism was linked to menthol preference in a genetic study (Uhl et al. 2011). The same polymorphism was found to increase irritant-induced TRPA1 responses and is linked to poorly controlled asthma in children, together with the R58T polymorphism. Variations resulting in chronic pain are localized to residues E179 and K188 (Deering-Rice et al. 2015). SNP = single nucleotide polymorphism; TRPA1 = transient receptor potential ankyrin 1.

Illustration is described in the notes for the figure.

In a study genotyping a cohort of 989 children with asthma, Deering-Rice and colleagues (2015) found a close correlation between poorly controlled asthma and homozygosity for the rs13268757 SNP in the TRPA1 gene, the same SNP resulting in the R3C mutation that is associated with preference for menthol cigarettes. The allele frequency of the mutation was 12.1% in the asthmatic cohort, and more than 50% of the homozygous cohort had poorly controlled asthma, defined by their failure to respond to corticosteroid treatment (Deering-Rice et al. 2015). Earlier, Mendiondo and colleagues (2010) used data from the nationally representative 2005 National Health Interview Survey to compare health status and menthol or nonmenthol cigarette status among adults who currently smoked (n = 3,949) and formerly smoked (n = 4,414). Compared with people who smoked nonmenthol cigarettes, a greater proportion of those who smoked menthol cigarettes had asthma (9.4% vs. 7.2%; p = 0.025). By race and ethnicity, Hispanic adults who smoked menthol cigarettes had a significantly higher prevalence of asthma than Hispanic adults who smoked nonmenthol cigarettes (13.0% vs. 4.5%; p <0.001). Although a higher prevalence of asthma was observed among Black (9.9% vs. 7.2%; p = 0.236) and non-Hispanic White (8.8% vs. 7.7%; p = 0.42) adults who smoked menthol cigarettes than among those who smoked nonmenthol cigarettes, these associations were not statistically significant. Additionally, people who formerly smoked menthol cigarettes were treated in emergency rooms for asthma 2.3 times more often than people who formerly smoked nonmenthol cigarettes in analyses adjusted for age, education, region, race and ethnicity, income, and sex. Although these data were cross-sectional, the findings suggest an increased risk of asthma exacerbations for menthol cigarette smoking compared with nonmenthol cigarette smoking.

The link between preference for menthol cigarettes and asthma and the involvement of TRPA1, the menthol or irritant receptor, in genetically determined disparities of flavor perception deserves further attention and research. Only one study (Uhl et al. 2011) has documented a possible link between a TRPA1 polymorphism and preference for menthol cigarettes, and data on TRPM8 gene variations have not been reported.

Additional validation studies of larger cohorts, preferably among people of different racial and ethnic backgrounds, are necessary to understand the significance of this finding. Compared with recent studies of pain genetics that used genomewide association studies with cohort sizes in the tens to hundreds of thousands, genetic studies on people who smoke menthol cigarettes remain limited in scope and have investigated candidate loci in only relatively small cohorts.

### Bitter Receptor Gene Variations in the TAS2R38 Gene Linked to Menthol Smoking in Female, Black or African American, Hispanic or Latino, and White People who Smoke

Variations in the genes encoding for the bitter receptors TAS2R38 and TAS2R16 have been linked to smoking status and nicotine addiction in people who use tobacco products (Mangold et al. 2008; Risso et al. 2016a). Menthol is thought to affect bitter taste perception, possibly reducing bitter sensation of nicotine (Lawrence et al. 2011). At the same time, menthol at certain levels can be perceived as bitter, and the flavor industry has pursued efforts to reduce such bitterness (Green and Schullery 2003; Slack and Pennimpede 2013) and balance the levels of both menthol and nicotine to appeal to consumers with different taster status.

Candidate gene studies of menthol smoking in people who smoke have investigated the effects of both TAS2R38 taster (PAV) and non-taster (AVI) haplotypes on menthol preference (Figure 3.12). The TAS2R38 bitter receptor PAV (taster) allele has been associated with menthol smoking in White women who smoke; Table 3.6 summarizes the studies that examined this finding. A 2015 study examined self-reported menthol smoking in 323 Hispanic and Caucasian women who were pregnant and participating in a smoking cessation trial (Oncken et al. 2015). PTC taster- or non-taster status was determined by genotyping of SNPs rs713598, rs1726866, and rs10246939 in the TAS2R38 gene, giving rise to either the PAV (taster) or AVI (nontaster) variant and other minor variants (Figure 3.12). The frequency of the PAV (taster) allele was higher in pregnant women who smoked menthol cigarettes than in those who smoked nonmenthol cigarettes: 54% versus 30% in non-Hispanic women and 53% versus 25% in Hispanic women (Oncken et al. 2015). Among test participants who were homozygous for the PAV (taster) haplotype, 85% of the non-Hispanic women and 100% of the Hispanic women had a high likelihood of smoking menthol cigarettes. An additive model, compared with recessive or dominant, fit best with the data for the non-Hispanic population group. This was the first study linking the TAS2R38 locus to the use of mentholated cigarettes, but the study was limited to Hispanic and Caucasian women.

Risso and colleagues (2017) examined the association between the use of menthol cigarettes and the taster and non-taster polymorphisms in TAS2R38 among 718 African American people who smoked (236 females and 482 males). Sequencing of the TAS2R38 reading frame noted a higher prevalence of intermediate haplotypes (AAI, AAV, PVI, and PAI) in addition to the PAV (taster) and AVI (non-taster) haplotypes. The study revealed a correlation between PAV (taster) alleles and the use of menthol cigarettes: the PAV allele was found in 48.2% of people who smoked menthol cigarettes and 42.1% of people who smoked nonmenthol cigarettes (p = 0.04). However, there was no complementary relationship between the increase in PAV haplotype and concomitant decrease of the AVI haplotype, likely because of the increased frequency of the intermediate haplotypes. Nevertheless, the frequency of the AVI (non-taster) haplotype was lower in people who smoked menthol cigarettes (29.8%) than in people who smoked nonmenthol cigarettes (37.7%). This association was observed in both men and women who smoked, and there was evidence of a statistically significant gene–dosage effect, as an increasing number of non-taster alleles correlated with nonmenthol smoking (Risso et al. 2017).

Figure 3.12 Polymorphic sites in the TAS2R38 bitter receptor, a determinant of menthol preference

Notes: TAS2R38 is the target of the bitter agents PTC and PROP. Three polymorphic sites in the Tas2r38 gene underlie the taster (PAV) and non-taster (AVI) haplotypes. The AVI variant is linked to nicotine dependence and heavy-smoking status, and the PAV taster variant is linked to menthol preference, likely due to suppression of bitterness perception.

Illustration is described in the notes for the figure.

In another study, people with the highest sensitivity to PROP, the so-called “supertasters” who are likely homozygous for the PAV haplotype, liked e-cigarettes containing menthol more than they liked other flavors of e-cigarettes. It is possible that genetic factors influencing menthol preference may be independent of the type of tobacco product (e.g., e-cigarettes or cigarettes) being used (Mead et al. 2019). Further investigation is warranted.

The tobacco industry has promoted the use of menthol cigarettes in African American communities for decades through targeted marketing (Stahre et al. 2010; Klausner 2011; Dauphinee et al. 2013; Sterling et al. 2016a). However, it remains unclear whether variations in the candidate genes, TRPA1 and TAS2R38 also contribute to the substantially higher prevalence of menthol cigarette smoking among African American people who smoke compared to White people who smoke. As noted previously in this chapter, the tobacco industry may rely on these underlying genetic factors and mechanisms in its targeted marketing of menthol cigarettes to specific groups.

### A Sensory Nerve Receptor Gene Variation in the MRGPRX4 Gene Linked to Menthol Smoking

A whole-exome sequence variation analysis led by a team from the National Institute on Deafness and Other Communication Disorders of the National Institutes of Health revealed strong evidence for genetic contributions to disparities in the menthol preferences of people who smoked (Kozlitina et al. 2019). This study investigated the association between exome sequence variations and menthol smoking in people who smoked, analyzing genetic samples from 561 study participants (394 African American people and 167 American people of European origin) from the Dallas Heart Study and the Dallas Biobank (Victor et al. 2004). Replication cohorts curated by the Schroeder Institute were derived from populations from the Washington, D.C., area. The analysis identified rs7102322, an African American-specific exome variation located in the MRGPRX4 gene (Mas-Related GPR family member X4), with strong associations to menthol smoking: a frequency of 8% in the Dallas cohorts and 5% in the Schroeder cohort. This variation was not found among American people of European origin in the control samples who smoked nonmenthol cigarettes. The rs7102322 appeared with 5- to 8-fold higher frequency among African American people, appearing among 10.4% of people who smoked menthol cigarettes versus 1.3% of people who smoked nonmenthol cigarettes in the Dallas cohort (odds ratio = 8.5), and among 7.0% of people who smoked menthol cigarettes versus 1.3% of people who smoked nonmenthol cigarettes in the Schroeder cohort (odds ratio = 6.3). The African American cohort from the Schroeder Institute had a lower overall frequency of rs7102322 because of its European American admixture. The minor allele frequency of rs7102322 was higher in African-ancestry populations (11.5 %) than it was in African American people in the southwest United States (8.0%). Complete exome sequencing of the MRGPRX4 gene in the Dallas cohort revealed that rs7102322 was in complete linkage disequilibrium with another exon sequence variation, rs61733596, that was also associated with menthol smoking (Kozlitina et al. 2019). In contrast to prior studies, this study examined ancestry and admixture from other ancestries in the study populations, relying on data from the 1000 Genomes Project.

Table 3.6 Associations between SNPs and menthol cigarette smoking

Study | Gene name | Function | SNP | Coding mutation | Menthol preference | Population | Frequency of people who smoke menthol cigarettes and OR
Oncken et al. (2015) | TAS2R38 | - Plays a role in the perception of bitterness; - Is linked to gustducin; - Mediates TRPM5 gating of bitter taste | - rs713598; - rs1726866; - rs10246939 | A49P, A262V, and V296I: AVI (non-taster) vs. PAV (taster) | PAV>AVI; Caucasian women who were pregnant and smoked menthol cigarettes had a greater number of PAV haplotypes compared with their counterparts who smoked nonmenthol cigarettes | - Non-Hispanic Caucasian women; - Hispanic Caucasian women | - Non-Hispanic Caucasian women:; – PAV (54%)>AVI (30%) for menthol preference; – OR = 3.02 (p = 0.001); - Hispanic Caucasian women:; – PAV (53%)>AVI (25%) for menthol preference; – OR = 3.60 (p = 0.020)
Risso et al. (2016b) | TAS2R38 | — | — | — | - AVI haplotype was inversely associated with menthol cigarette smoking; - PAV haplotype was associated with menthol cigarette smoking | African American | - AVI:; – People who smoked menthol cigarettes = 29.8%; – People who smoked nonmenthol cigarettes = 37.7%; – OR (overall): 0.70 (p = 0.08); – OR (males): 0.72 (p = 0.01); – OR (females): 0.89 (p = 0.01); – Copies of haplotypes:; ○ 0 = 62.3%; ○ 1 = 53.8%; ○ 2 = 44.0%; - PAV:; – People who smoked menthol cigarettes = 48.2%; – People who smoked nonmenthol cigarettes = 42.1%; – OR = 1.24 (p = 0.04)
Uhl et al. (2011) | TRPA1 | Nonselective cationic TRP ion channel involved in chemical sensing, inflammatory pain, mechanical stress, and possibly in cold perception | - rs13268757 (exon1); - rs10111216; - rs4738205; - rs1373297; - rs1443952; - rs12677736; - rs10101155; - rs12548486; - rs4737338; - rs1373302; - rs3824150 (intron SNPs) | Exon1 (R to C missense mutation) | - Minor allele encoding for the missense cysteine had inverse preference for mentholated cigarettes in people who smoked heavily; - Ten other intronic SNPs had preference for mentholated cigarettes in people who smoked heavily; - Overall, the haplotype displays significant association with menthol cigarette preference in people who smoked heavily | - American people of European origin who smoked:; – Heavily (>15 cigarettes smoked per day); – Lightly (≤15 cigarettes per day) | - Menthol preference was associated with 4–7% higher minor allele frequencies for 10 intronic SNPs; - Exon 1 missense SNP had an opposite association, with a 4.2% lower menthol preference; - OR = 1.3 (p = 0.006)
Kozlitina et al. (2019) | MRGPRX4 | G-protein-coupled receptor expressed in sensory neurons that are involved in nociception and somatosensation | - rs7102322[G] and rs61733596[G]:; – Minor allele = G; – Major allele = A; - Exclusive to those of African ancestry | - N245S (for rs7102322[G]); - T43T (for rs61733596[G]) | Associated with menthol smoking behavior | Multiethnic population and African American people | - N245S (for rs7102322[G]):; – 7.0–10.4% (menthol) vs.1.3% (nonmenthol); – OR = 5–8 (p = 0.000056); - T43T (for rs61733596[G]):; – 6.6% (menthol) vs.1.5% (nonmenthol); – OR = 3.3 (p = 0.007)

Notes: AVI = Ala49Val262Ile296; OR = odds ratio; PAV = Pro49Ala262Val296; SNP = single nucleotide polymorphism.

MRGPRX4 encodes for a GPCR of the Mas-related GPCR (MRGPCR) family (Figure 3.13). MRGPRs were initially identified in peripheral sensory neurons, with some family members labeling neuronal subtypes involved in itch signaling (Dong et al. 2001; Meixiong and Dong 2017). The sensation of itch (pruritus)—in response to environmental irritants, mast cell degranulation (which releases histamine), and non-histaminergic pathways—is triggered by pruriceptors, which are specialized sensory nerves with circuitries distinct from the nociceptors that initiate the sensation of pain (Bautista et al. 2014). However, pruriceptors and nociceptors share similar signaling mechanisms, including such ion channels as TRPA1 and TRPV1 (Bautista et al. 2014). Some MRGPRs are directly activated by itch-inducing agents, including such drugs as chloroquine, leading to downstream activation of TRPA1 (Wilson et al. 2011; Bautista et al. 2014). Although MRGPRs are known for their functional roles in skin-innervating neurons, they are also expressed in sensory nerves innervating the respiratory system and thus may sense tobacco product flavors and other constituents of cigarette smoke.

Figure 3.13 Polymorphic sites in the MRGPRX4 G-protein coupled receptor linked to menthol preference in African American people who smoke

Notes: MRGPRX4 (Mas-related G-protein-coupled receptor X4) is a member of the MRG receptor family expressed in peripheral sensory neurons. The polymorphism, rs7102322, induces an amino acid change, N245S, in the third extracellular loop of the receptor, leading to diminished responses to the synthetic ligand, Nateglinide. (Nateglinide is also a clinically approved drug for type II diabetes.) This polymorphism is present exclusively in African American people, with a frequency of 5–8%, and African American people who smoke menthol cigarettes have a 5- to 8-fold higher likelihood of carrying this variation.

Illustration is described in the notes for the figure.

The MRGPR gene family shows rapid evolutionary divergence. Mice have 27 MRGPR genes, with seven subfamilies and almost the same number of pseudogenes, but the human genome contains only eight intact genes of the MRGPR gene family (Meixiong and Dong 2017). MRGPRX4 is a member of the human MRGPRX gene subfamily with four members and is most closely related to the murine MRGPRA family. However, sequence divergence does not allow assignments of corresponding species orthologues between humans and mice (Meixiong and Dong 2017).

The MRGPRX4 gene is expressed in dorsal root ganglia, suggesting that the receptor may be involved in sensory mechanisms (Kozlitina et al. 2019; Meixiong et al. 2019). A functional pharmacological screen identified MRGPRX4 as a target of nateglinide, a drug used to treat type II diabetes, where it acts as an inhibitor of ATP (adenosine triphosphate)-regulated potassium channels in pancreatic beta-cells. Nateglinide produces an itch as a side effect in some patients through a mechanism that may involve MRGPRX4. A study in models of cholestatic itch, often observed in jaundice patients, revealed that MRGPRX4 is activated by bilirubin that is enriched in patient blood (Meixiong et al. 2019). Inhibition of MRGPRX4 may be a strategy to relieve pruritus associated with jaundice and other conditions activating this receptor (Meixiong et al. 2019).

The exonic variation rs7102322, associated with preference for menthol smoking, induces a point mutation (N245S) in the third extracellular loop of the MRGPR receptor (Figure 3.13) (Kozlitina et al. 2019). In many GPCRs, this loop is involved in ligand binding. In a function test of beta-arrestin recruitment, nateglinide clearly activated heterologously expressed MRGPRX4 receptors (Kozlitina et al. 2019). The mutant showed strongly diminished responses to nateglinide (64% reduction). Menthol, at 100 μM (micromolar) concentrations, had a modest inhibitory effect on activation of MRGPRX4 by nateglinide, but 300 μM of menthol concentration diminished activation by 40–50%. Menthol also affected basal activity of MRGPRX4, increasing basal signaling (Kozlitina et al. 2019). These findings suggest that menthol may be a partial agonist of MRGPRX4.

The variation rs7102322 in the MRGPRX4 gene, found solely in individuals of African ancestry, has the highest odds ratio among the genetic variations associated with disparities in menthol smoking, increasing the odds of menthol use 5- to 8-fold among people who smoke cigarettes (Kozlitina et al. 2019). The localization of MRGPRX4 gene transcription in peripheral sensory neurons suggests that the receptor may be involved in the sensing of exogenous or endogenous stimuli associated with smoking and/or in the sensing of menthol. The concentrations of menthol required to inhibit receptor activation, or increase basal activity, are comparably high (100 μM or higher). The discovery of bilirubin, which is elevated in jaundice, as a potential endogenous agonist of MRGPRX4 is intriguing, but its agonist activity is weaker than that of nateglinide. Studies of levels of bilirubin in relation to smoking have shown that blood levels of bilirubin are lower in people who smoke than in people who do not smoke. Low levels of bilirubin indicate a slower onset of chronic obstructive pulmonary disease but are correlated with a higher likelihood of developing lung cancer in people who smoke (Apperley et al. 2015; Wen et al. 2015; Kodal et al. 2020). Further screens are needed to identify additional ligands of MRGPRX4, which should include the testing of flavors for tobacco products and their constituents. It is also critical to characterize the sensory nerve subtypes in which MRGPRX4 is expressed, the endogenous signaling pathways engaged by this receptor, and the coupled ion channels that may further integrate menthol signaling. Because of the rapid evolutionary divergence of MRG receptor genes, MRGPRX4 in humans has no clear species ortholog in rodents, complicating the analysis of this pathway in model systems. Humanized transgenic systems may be needed to facilitate further studies of the role of this key receptor in determining menthol preference.

## Summary of the Evidence

This chapter summarizes the current knowledge about the chemosensory and physiological mechanisms through which menthol and other flavor chemicals in tobacco products act, and the genetic factors that may influence these mechanisms and may contribute to flavored tobacco product use disparities. This research may help to explain the appeal of flavored tobacco products that elicit multisensory experiences among youth, women, and certain racial and ethnic groups. Scientific data suggest that a consumer’s use of flavored tobacco products, including menthol, is not arbitrary. Instead, use of flavored tobacco products can be explained by a range of factors, including prior conditioning to prefer certain flavors, differences in taster status and genetics, and targeted marketing. The review in this chapter, in conjunction with prevalence data and marketing data presented elsewhere in this report, provides a greater understanding of why certain groups of people may be more likely to use flavored tobacco products than other groups and how this use influences tobacco-related health disparities along the tobacco use continuum.

Research and regulation of tobacco products that are menthol flavored, a known flavor of concern in tobacco products, could serve as models to address other tobacco product flavorants, including the many minty and cooling agents that have been developed by the flavor industry. Varying levels of natural or synthetic coolers and refreshers, in combination with different chemicals, can have long-lasting effects on various parts of the body, even different parts of the oral cavity. The combination of some cooling chemicals can invoke more intense cooling. Additionally, cooling chemicals at different levels can invoke fruity notes or prolong sweetness (Table 3.4).

Menthol and other chemicals in tobacco products act on the trigeminal and vagus nerves and activate various receptors to induce cooling, pain, irritant, and heat sensations. TRPM8, a TRP receptor, is activated by cold, menthol, and numerous other cooling agents used as additives in tobacco products. TRPA1, another TRP receptor, is activated by chemicals found in tobacco smoke and by numerous flavor additives, including menthol and methyl salicylate.

Depending on taster status, some groups of people are more likely than other groups to like particular flavor experiences, including menthol and the bitter taste of nicotine, resulting in different flavor preferences among gender, age, and racial and ethnic groups. In addition, the tobacco industry’s use of synthetic and natural sweeteners makes tobacco products less aversive among people with different taste sensitivities. Along with the physiological, chemosensory, and genetic influences on menthol cigarette use, social factors, such as decades of targeted marketing, also influence initiation and maintenance of smoking menthol-flavored tobacco products. Individuallevel biological factors combined with additional factors at the individual, interpersonal, community (e.g., retailers), societal (e.g., tobacco manufacturing, marketing and distribution) and policy (e.g., regulation of sale, manufacturing, and marketing) levels influence tobacco-related health disparities.

As of 2022, variations in three genetic loci—TRPA1, TAS2R38, and MRGPRX4—have been identified that may contribute to differences in menthol preference and, potentially, to disparities in menthol preference in people who smoke. The odds ratio—the likelihood a certain behavior, such as menthol preference, is observed if the determining genetic variation is present or absent—is less than two-fold for the variations in the TRPA1 and TAS2R38 genes in the cohorts investigated (White people who smoke heavily and Hispanic women who smoke, respectively). For the polymorphism in the MRGPRX4, the odds ratio associated with menthol smoking is higher, with 5- to 8-fold increased odds of menthol smoking in the investigated cohorts of Black or African American people who smoke. However, to date, these genetic studies are restricted to small cohorts, and, thus, more expansive and diverse samples are needed to extrapolate to the population level.

The MRGPRX4 gene polymorphism associated with menthol preference was present in about 7–10% of people who smoked menthol cigarettes in the investigated cohorts of people of African ancestry (Kozlitina et al. 2019). The prevalence of this MRGPRX4 variant in people of African ancestry who smoke menthol is substantially lower than (a) the prevalence of menthol cigarette smoking African American people who smoke (88.1%) and (b) the overall prevalence of menthol smoking among all people who smoke in the United States (42.1%) (see Table 2.6 in Chapter 2), suggesting that additional factors may contribute to menthol preference (Kozlitina et al. 2019). A genuine big data approach with large cohorts is needed to explore multigenic linkages (He et al. 2017). Large scale genetic studies are likely to increase understanding of underlying genetic determinants that interact with other factors—such as marketing, cigarette engineering, and physiological factors—to influence the use of menthol cigarettes and the behaviors toward other flavors and additives. Underlying genetic factors should be studied in context with pharmacological data and marketing influences to obtain a comprehensive understanding of how flavors influence tobacco use and tobacco-related health disparities, as such factors may interact to explain the disproportionate use of menthol among African American people, Native Hawaiian and Pacific Islander people, youth, women, people who identify as LGBTQI+, and population groups with lower incomes. Future research that examines genetic, pharmacologic, and marketing influences together would help the field to understand the mechanisms and pathways to tobacco-related health disparities.

Additional research on these topics could further elucidate underlying genetic, biological, physiological, and chemosensory mechanisms of flavor and other chemicals on tobacco use and tobacco-related diseases and conditions. However, the scientific evidence to justify prohibiting the marketing, sales, and distribution of menthol tobacco products and flavored cigars has been both substantial and sufficient for years.

Menthol in tobacco smoke has pharmacological effects beyond the somatosensory effects discussed in the context of the TRPA1 and TRPM8 ion channels. First, the counterirritant effects of menthol on respiratory sensory innervation could partly explain why menthol increases the likelihood of smoking initiation among adolescents. Second, new data suggest that menthol can reach sufficient concentrations in the central nervous system to affect the dopaminergic reward circuitry by interacting with nicotinic acetylcholine receptors. Third, menthol acts as a cue and reinforcer of nicotine intake. These effects may partly explain why people who smoke menthol cigarettes have more difficulty quitting smoking and have higher relapse rates after quitting menthol smoking than people who smoke nonmentholated cigarettes. Accumulating evidence demonstrates that the effects of menthol extend to both smokeless tobacco products and e-cigarettes that are flavored with menthol.

This chapter discussed a range of existing natural and synthetic flavor chemicals, factors that contribute to multisensory experiences, and other physiological and genetic factors that influence flavor and sensory detection and reactions. The tobacco industry uses flavors—including menthol—in their products; the flavors help to increase the appeal of tobacco products, especially among individuals and groups with higher aversions to the effects of tobacco smoke. Industry documents described in this chapter demonstrate that tobacco companies have known for decades that the sensory (e.g., cooling, numbing) properties of menthol play a central role in increasing the appeal of smoking. Together, the findings in this chapter can help to inform local, state, and federal efforts to regulate flavors in tobacco products, as described in Chapters 7 and 8.

As discussed in Chapters 6 and 7, prohibiting flavored tobacco products, including menthol, would reduce the overall prevalence of tobacco product use and particularly menthol tobacco product use, especially among individuals and groups with higher aversions to the effects of tobacco smoke. However, efforts to prohibit menthol tobacco products without considering alternative natural cooling agents (e.g., eucalyptol, isopulegol, carvone); synthetic cooling agents (e.g., WS series and other coolants), some of which have little or no taste or odor; noncooling or minimally cooling mint flavorants, such as menthone; and other multisensory chemical additives may compromise efforts to reduce tobacco-related health disparities. Synthetic cooling agents recently detected in combustible cigarettes and nicotine pouches and openly marketed by vendors of e-liquids mimic the cooling and counterirritant effects of menthol and allow combination within non-mint-flavored products, especially fruit- and candy-flavored products that are popular with adolescents and young adults.

In addition, the use of highly potent synthetic sweeteners in tobacco products raises concerns about cumulative intake of sweeteners. Smokeless tobacco products are intensely sweetened to help mask the aversive tastes during oral consumption of such products. Synthetic sweeteners can also be found in high concentrations in the mouthpieces of cigars and cigarillos which are marketed in sweet, candy, and fruit flavors. Because children and adolescents exhibit stronger preferences for sweet tastes compared with adults, considering sweetness as a flavor and eliminating all sweeteners in tobacco products would be expected to reduce the likelihood of youth initiation and transition to tobacco dependence, protect certain population groups from tobacco-related health disparities, prevent potential chronic metabolic effects of artificial sweeteners, and limit exposure to sweeteners at potentially adverse effect levels.

Many chemical additives that have been identified in tobacco products—such as WS-3, WS-23, and other synthetic cooling agents—are devoid or nearly devoid of taste and odor and thus might not be considered flavors under a narrow definition that looks at only taste and odor. Comprehensive efforts to address the appeal of tobacco products could maximize public health benefits and minimize risks by considering odorless flavorants (such as sweeteners), synthetic cooling agents, and the pharmacologic actions of flavorants and chemical additives. Importantly, FDA identified, under its proposed menthol cigarette and flavored cigar product standards in 2022, several factors that are relevant in determining whether a cigarette or cigar would have a characterizing flavor: the presence and amount of artificial or natural flavoring ingredients in a tobacco product, including its components or parts; the multisensory experience (i.e., taste, aroma, and cooling or burning sensations in the mouth and throat) of a flavor during use of a tobacco product, including its components or parts; implicit or explicit flavor representations, including descriptors, on packaging and in advertising; and any other means that impart flavor or represent that the tobacco product has a characterizing flavor.

Science-based regulations of flavors that make tobacco products more palatable to new and existing consumers are important for protecting the public’s health. Regulatory frameworks that consider the pharmacological effects of menthol and other flavorants; cooling and refreshing or pain-desensitizing chemicals; sweeteners; and the emerging genetic evidence for the disparate pharmacological actions of flavorants in youth, women, and racial and ethnic population groups could help to reduce tobacco-related health disparities. The biological mechanisms of action of chemical additives—as an odorant, tastant, somatosensory agent, sensory modulator, modulator of reward circuitry, or toxicant—create opportunities to further investigate additives, compounds, constituents, and other ingredients that facilitate tobacco use. This could include considering how genetic modifications of tobacco to include flavors and the processing of tobacco—such as bending various types of tobacco and adding flavor chemicals to the casing (sugar, licorice, cocoa) and other dressings (spices, sweeteners)—contribute to the taste, odor, attractiveness, and multisensory experiences of people who use tobacco products or who may be vulnerable to tobacco use. Notwithstanding, scientific evidence from multiple disciplines justifies comprehensive prohibitions on the manufacturing, distribution, marketing, and sales of flavored tobacco products.

## Conclusions

1. The evidence is sufficient to infer that some natural and synthetic chemicals and flavorants that are added to tobacco products have pharmacological effects; act as cues and reinforcers; and, in some cases, act centrally to modulate the brain reward circuitry.
2. Natural and synthetic chemicals and flavorants added to tobacco products elicit multisensory experiences, including odorant (olfactory) effects; basic taste perceptions (e.g., sweet, bitter); and somatosensory effects, such as cooling.
3. Sweeteners are used in tobacco products to mask aversive tastes and have been detected at high levels in certain oral tobacco products. Sweet taste appeals more to young people than to older people.
4. Smoking status; use of flavored tobacco products; and related disparities by age, gender, and race and ethnicity result from multilevel influences. Targeted marketing, societal and cultural factors, and genetic variations that affect underlying chemosensory and physiological mechanisms result in differences in the appeal of and ability to perceive certain flavor qualities, such as bitter taste.
5. Determinations that flavorants are “generally recognized as safe” for use in foods are not applicable to the inhalation of tobacco products. These ingredients, when inhaled, may be directly toxic to the lungs or could result in higher absorption of toxicants. Commonly used natural and synthetic chemicals and flavorants may be safe to ingest in foods but might be harmful when inhaled.
6. Animal studies suggest that menthol and sweeteners influence nicotine uptake. Menthol and other flavorants, such as farnesene and farnesol, directly affect the dopaminergic reward circuitry and may potentiate the addictive effects of nicotine.
7. Natural and synthetic cooling agents that have been found in some tobacco products (a) act on different parts of the oral cavity and the respiratory system to enhance the experience of smoking or use of other tobacco products and (b) can mimic the pharmacological and somatosensory effects of menthol but may not have a distinguishing taste or odor. Cooling agents, even those without a taste or odor, have the potential to increase the appeal of tobacco products, facilitate their use, and contribute to tobacco-related health disparities. Comprehensive flavor policies that account for these agents will better protect public health.
8. Genetic studies provide suggestive evidence that variations in genes involved in sensory mechanisms and taste perception may influence menthol smoking in youth, women, and some minoritized racial and ethnic groups. The emerging science on the role of genes in flavor experiences should be understood in context with multilevel commercial, societal, and cultural factors that influence tobacco-related health disparities.

## References

Abad-Vivero EN, Thrasher JF, Arillo-Santillan E, Perez-Hernandez R, Barrientos-Gutierrez I, Kollath-Cattano C, Mejia R, Sargent JD. Recall, appeal and willingness to try cigarettes with flavour capsules: assessing the impact of a tobacco product innovation among early adolescents. Tobacco Control 2016;25(e2):e113–e9.27060099
Ai J, Taylor KM, Lisko JG, Tran H, Watson CH, Holman MR. Menthol content in U.S. marketed cigarettes. Nicotine & Tobacco Research 2016;18(7):1575–80.26259988
Ajagannanavar SL, Battur H, Shamarao S, Sivakumar V, Patil PU, Shanavas P. Effect of aqueous and alcoholic licorice (glycyrrhiza glabra) root extract against streptococcus mutans and lactobacillus acidophilus in comparison to chlorhexidine: an in vitro study. Journal of International Oral Health 2014;6(4):29–34.25214729
Alarie Y. Irritating properties of airborne materials to the upper respiratory tract. Archives of Environmental Health 1966;13(4):433–49.5921282
Alarie Y, Schaper M, Nielsen GD, Abraham MH. Structureactivity relationships of volatile organic chemicals as sensory irritants. Archives of Toxicology 1998;72(3):125–40.9520136
Ali FRM, Diaz MC, Vallone D, Tynan MA, Cordova J, Seaman EL, Trivers KF, Schillo BA, Talley B, King BA. E-cigarette unit sales, by product and flavor type—United States, 2014–2020. Morbidity and Mortality Weekly Report 2020;69(37):1313–8.32941416
Ali FRM, Seaman EL, Diaz MC, Ajose J, King BA. Trends in unit sales of cooling flavoured e-cigarettes, U.S.A., 2017–2021. Tobacco Control 2022.
Alpert HR, Agaku IT, Connolly GN. A study of pyrazines in cigarettes and how additives might be used to enhance tobacco addiction. Tobacco Control 2016;25(4):444–50.26063608
Anderson A, McConville A, Fanthorpe L, Davis J. Salicylate poisoning potential of topical pain relief agents: from age old remedies to engineered smart patches. Medicines (Basel) 2017;4(3):48.28930263
Andrè E, Campi B, Materazzi S, Trevisani M, Amadesi S, Massi D, Creminon C, Vaksman N, Nassini R, Civelli M, . Cigarette smoke-induced neurogenic inflammation is mediated by alpha,beta-unsaturated aldehydes and the TRPA1 receptor in rodents. Journal of Clinical Investigation 2008;118(7):2574–82.18568077
Apperley S, Park HY, Holmes DT, Man SFP, Tashkin D, Wise RA, Connett JE, Sin DD. Serum bilirubin and disease progression in mild COPD. Chest 2015;148(1):169–75.25539285
Arabi Z. An epidemic that deserves more attention: epidemiology, prevention, and treatment of smokeless tobacco. Southern Medical Journal 2007;100(9):890–4.17902289
Ashoor A, Nordman JC, Veltri D, Yang KH, Al Kury L, Shuba Y, Mahgoub M, Howarth FC, Sadek B, Shehu A, . Menthol binding and inhibition of alpha7-nicotinic acetylcholine receptors. PLoS One 2013;8(7):e67674.23935840
Avelar AJ, Akers AT, Baumgard ZJ, Cooper SY, Casinelli GP, Henderson BJ. Why flavored vape products may be attractive: green apple tobacco flavor elicits reward-related behavior, upregulates nAChRs on VTA dopamine neurons, and alters midbrain dopamine and GABA neuron function. Neuropharmacology 2019;158:107729.31369741
Bagdas D, Jackson A, Carper M, Chen RY, Akinola LS, Damaj MI. Impact of menthol on nicotine intake and preference in mice: concentration, sex, and age differences. Neuropharmacology 2020;179:108274.32827516
Baker RR. Product formation mechanisms inside a burning cigarette. Progress in Energy and Combustion Science 1981;7(2):135–53.
Bandell M, Dubin AE, Petrus MJ, Orth A, Mathur J, Hwang SW, Patapoutian A. High-throughput random mutagenesis screen reveals TRPM8 residues specifically required for activation by menthol. Nature Neuroscience 2006;9(4):493–500.16520735
Barragán R, Coltell O, Portoles O, Asensio EM, Sorli JV, Ortega-Azorin C, Gonzalez JI, Saiz C, Fernandez-Carrion R, Ordovas JM, . Bitter, sweet, salty, sour and umami taste perception decreases with age: sex-specific analysis, modulation by genetic variants and taste-preference associations in 18 to 80 year-old subjects. Nutrients 2018;10(10).
Bartoshuk LM. Bitter taste of saccharin related to the genetic ability to taste the bitter substance 6-n-propylthiouracil. Science 1979;205(4409):934–5.472717
Bautista DM, Jordt SE, Nikai T, Tsuruda PR, Read AJ, Poblete J, Yamoah EN, Basbaum AI, Julius D. TRPA1 mediates the inflammatory actions of environmental irritants and proalgesic agents. Cell 2006;124(6):1269–82.16564016
Bautista DM, Wilson SR, Hoon MA. Why we scratch an itch: the molecules, cells and circuits of itch. Nature Neuroscience 2014;17(2):175–82.24473265
Bavan S, Kim CH, Henderson BJ, Lester HA. Chronic menthol does not change stoichiometry or functional plasma membrane levels of mouse alpha3beta4-containing nicotinic acetylcholine receptors. Molecular Pharmacology 2019;95(4):398–407.30670481
Behrendt HJ, Germann T, Gillen C, Hatt H, Jostock R. Characterization of the mouse cold-menthol receptor TRPM8 and vanilloid receptor type-1 VR1 using a fluorometric imaging plate reader (FLIPR) assay. British Journal of Pharmacology 2004;141(4):737–45.14757700
Bell RA, Spangler JG, Quandt SA. Smokeless tobacco use among adults in the Southeast. Southern Medical Journal 2000;93(5):456–62.10832940
BeMiller JN. Carbohydrate Chemistry for Food Scientists. 3rd ed. Duxford (England): Woodhead Publishing and AACC International Press, 2018.
Benemei S, Fusi C, Trevisan G, Geppetti P. The TRPA1 channel in migraine mechanism and treatment. British Journal of Pharmacology 2014;171(10):2552–67.24206166
Benowitz NL, Herrera B, Jacob P 3rd. Mentholated cigarette smoking inhibits nicotine metabolism. Journal of Pharmacology and Experimental Therapeutics 2004;310(3):1208–15.15084646
Berenstein N. Flavor added: the sciences of flavor and the industrialization of taste in America [dissertation], 2017; <https://repository.upenn.edu/handle/20.500.14332/29662>; accessed: July 3, 2023.
Biener L, Bogen K. Receptivity to Taboka and Camel snus in a U.S. test market. Nicotine & Tobacco Research 2009;11(10):1154–9.19564175
Biener L, Roman AM, Mc Inerney SA, Bolcic-Jankovic D, Hatsukami DK, Loukas A, O’Connor RJ, Romito L. Snus use and rejection in the U.S.A. Tobacco Control 2016;25(4):386–92.24570100
Birdsey J, Cornelius M, Jamal A, Park-Lee E, Cooper MR, Wang J, Sawdey MD, Cullen KA, Neff L. Tobacco product use among U.S. middle and high school students—National Youth Tobacco Survey, 2023. Morbidity and Mortality Weekly Report 2023;72(44):1173–82.37917558
Bonhomme MG, Holder-Hayes E, Ambrose BK, Tworek C, Feirman SP, King BA, Apelberg BJ. Flavoured non-cigarette tobacco product use among U.S. adults: 2013–2014. Tobacco Control 2016;25:(Suppl 2):ii4–ii13.27794065
Bono RS, Cobb CO, Wall CS, Lester RC, Hoetger C, Lipato T, Guy MC, Eissenberg T, Bickel WK, Barnes AJ. Behavioral economic assessment of abuse liability for Black & Mild cigar flavors among young adults. Experimental and Clinical Psychopharmacology 2022;30(1):113–9.33001692
Booth JN. Heating up the flavours category. Tobacco Journal International 2018;3:88–9.
Boukalova S, Touska F, Marsakova L, Hynkova A, Sura L, Chvojka S, Dittert I, Vlachova V. Gain-of-function mutations in the transient receptor potential channels TRPV1 and TRPA1: how painful? Physiological Research 2014;63(Suppl 1):S205–S213.24564660
Brain KR, Green DM, Dykes PJ, Marks R, Bola TS. The role of menthol in skin penetration from topical formulations of ibuprofen 5% in vivo. Skin Pharmacology and Physiology 2006;19(1):17–21.16247245
Brandt AM. Inventing conflicts of interest: a history of tobacco industry tactics. American Journal of Public Health 2012;102(1):63–71.22095331
British American Tobacco Company. Artificial Sweeteners. March 15, 1968. British American Tobacco Collection. Bates No. 100658527-100658528. <https://www.industrydocuments.ucsf.edu/docs/nggb0200>.
Brown & Williamson. Taste Segmentation Study Final Report. May 1984. Product Design MSA Collection. Bates No. 538003902-538003933. <https://www.industrydocuments.ucsf.edu/docs/fgdj0037>.
Brown & Williamson. Cooling Agent 10 3-l-Menthoxy Propan-1, 2-diol (MPD) as an Excellent Cooling Agent. 1990. MSA Collection. Bates No. 397121951-397121960. <https://www.industrydocuments.ucsf.edu/tobacco/docs/#id=mryl0225>.
Brown JE, Luo W, Isabelle LM, Pankow JF. Candy flavorings in tobacco. New England Journal of Medicine 2014;370(23):2250–2.24805984
Buchting FO, Emory KT, Scout, Kim Y, Fagan P, Vera LE, Emery S. Transgender use of cigarettes, cigars, and e-cigarettes in a national study. American Journal of Preventive Medicine 2017;53(1):e1–e7.28094133
Burdock GA, Fenaroli G. Fenaroli’s handbook of flavor ingredients. 6th ed. Boca Raton (FL): CRC Press/Taylor & Francis Group, 2010.
Caceres AI, Brackmann M, Elia MD, Bessac BF, del Camino D, D’Amours M, Witek JS, Fanger CM, Chong JA, Hayward NJ, . A sensory neuronal ion channel essential for airway inflammation and hyperreactivity in asthma. Proceedings of the National Academy of Sciences of the United States of America 2009;106(22):9099–104.19458046
Cantrell DV, Brown L. Camel Orbs Fresh vs. Breezer Prototype Qualitative Consumer Evaluation Panel (Proposal #0905). July 1, 2009. R.J. Reynolds Collection. Bates No. 545485184-545485212. <https://www.industrydocuments.ucsf.edu/docs/qhlx0225>.
Cantrell DV, Morgan W. Interim Report—Camel Snus Aging Study Results After 16 of 30 Weeks. October 3, 2006. R.J. Reynolds Collection. Bates No. 546237923-546237981. <https://www.industrydocuments.ucsf.edu/docs/mlkx0225>.
Cantrell J, Kreslake JM, Ganz O, Pearson JL, Vallone D, Anesetti-Rothermel A, Xiao H, Kirchner TR. Marketing little cigars and cigarillos: advertising, price, and associations with neighborhood demographics. American Journal of Public Health 2013;103(10):1902–9.23948008
Caraballo RS, Asman K. Epidemiology of menthol cigarette use in the United States. Tobacco Induced Diseases 2011;9(Suppl 1):S1.21624147
Carmines EL, Lemus R, Gaworski CL. Toxicologic evaluation of licorice extract as a cigarette ingredient. Food and Chemical Toxicology 2005;43(9):1303–22.15878225
Carpenter CM, Wayne GF, Pauly JL, Koh HK, Connolly GN. New cigarette brands with flavors that appeal to youth: tobacco marketing strategies. Health Affairs 2005;24(6):1601–10.16284034
Center for Drug Evaluation and Research. Assessment of Abuse Potential of Drugs: Guidance for Industry. Silver Spring (MD): U.S. Department of Health and Human Services, U.S. Food and Drug Administration, January 2017.
Center for Tobacco Products. Scientific Review of the Effects of Menthol in Cigarettes on Tobacco Addiction: 1980–2021, 2022; <https://www.fda.gov/media/157642/download>; accessed: May 17, 2022.
Chan TY. Potential dangers from topical preparations containing methyl salicylate. Human & Experimental Toxicology 1996;15(9):747–50.8880210
Chang CM, Corey CG, Rostron BL, Apelberg BJ. Systematic review of cigar smoking and all cause and smoking related mortality. BMC Public Health 2015;15:390.25907101
Chasman DI, Anttila V, Buring JE, Ridker PM, Schurks M, Kurth T. Selectivity in genetic association with sub-classified migraine in women. PLoS Genetics 2014;10(5):e1004366.24852292
Chasman DI, Schurks M, Anttila V, de Vries B, Schminke U, Launer LJ, Terwindt GM, van den Maagdenberg AM, Fendrich K, Volzke H, . Genome-wide association study reveals three susceptibility loci for common migraine in the general population. Nature Genetics 2011;43(7):695–8.21666692
Chen C, Isabelle LM, Pickworth WB, Pankow JF. Levels of mint and wintergreen flavorants: smokeless tobacco products vs. confectionery products. Food and Chemical Toxicology 2010;48(2):755–63.20034536
Chen C, Luo W, Isabelle LM, Gareau KD, Pankow JF. The stereoisomers of menthol in selected tobacco products. A brief report. Nicotine & Tobacco Research 2011;13(8):741–5.21447840
Cheng YC, Rostron BL, Day HR, Stanton CA, Hull LC, Persoskie A, Travers MJ, Taylor K, Conway KP, Ambrose BK, . Patterns of use of smokeless tobacco in U.S. adults, 2013–2014. American Journal of Public Health 2017;107(9):1508–14.28727534
Cho YJ, Thrasher JF. Flavour capsule heat-sticks for heated tobacco products. Tobacco Control 2019;28(e2):e158–e159.30217960
Chuang HH, Neuhausser WM, Julius D. The super-cooling agent icilin reveals a mechanism of coincidence detection by a temperature-sensitive TRP channel. Neuron 2004;43(6):859–69.15363396
Cigar Association of America v. FDA, No. 16-cv-01460, Docket No. 277 (D.D.C. Aug. 9, 2023).
Clark GS. Aroma chemical profile—menthol. Perfumer & Flavorist 2007;32(12):32–47.
Cliff MA, Green BG. Sensory irritation and coolness produced by menthol: evidence for selective desensitization of irritation. Physiology & Behavior 1994;56(5):1021–9.7824566
Code of Federal Regulations. Title 21 (food and drugs), chapter 1 (Food and Drug Administration, Department of Health and Human Services), subchapter B (food for human consumption), 2023; <https://www.ecfr.gov/current/title-21/chapter-I/subchapter-B>; accessed: July 24, 2023.
Cohn A, Johnson A, Pearson J, Rose S, Ehlke S, Ganz O, Niaura R. Determining non-cigarette tobacco, alcohol, and substance use typologies across menthol and non-menthol smokers using latent class analysis. Tobacco Induced Diseases 2017;15:5.28105000
Connolly GN, Wayne GD, Lymperis D, Doherty MC. How cigarette additives are used to mask environmental tobacco smoke. Tobacco Control 2000;9(3):283–91.10982572
Consolidated Appropriations Act, Public Law 117-103, U.S. Statutes at Large 136 (2022): 789; Division P, Title I, Subtitle B, § 111.
Cooper SY, Akers AT, Henderson BJ. Green apple e-cigarette flavorant farnesene triggers reward-related behavior by promoting high-sensitivity nAChRs in the ventral tegmental area. eNeuro 2020;7(4):4223.
Cooper SY, Akers AT, Henderson BJ. Flavors enhance nicotine vapor self-administration in male mice. Nicotine & Tobacco Research 2021;23(3):566–72.32860507
Cooper SY, Henderson BJ. The impact of Electronic Nicotine Delivery System (ENDS) flavors on nicotinic acetylcholine receptors and nicotine addiction-related behaviors. Molecules 2020;25(18).
Cornacchione J, Wagoner KG, Wiseman KD, Kelley D, Noar SM, Smith MH, Sutfin EL. Adolescent and young adult perceptions of hookah and little cigars/cigarillos: implications for risk messages. Journal of Health Communication 2016;21(7):818–25.27337629
Cornelius ME, Loretan CG, Wang TW, Jamal A, Homa DM. Tobacco product use among adults—United States, 2020. Morbidity and Mortality Weekly Report 2022;71(11):397–405.35298455
Craver R. Reynolds turns to ‘fresh, crisp’ for marketing traditional cigarettes in California, Winston-Salem Journal, January 23, 2023; <https://journalnow.com/reynolds-turns-to-fresh-crisp-for-marketing-traditional-cigarettes-in-california/article_70d932f6-9b3e-11ed-8ec3-87e068d5186f.html>; accessed: July 5, 2023.
Creative Research Group Limited. Project Crawford: Phase 1:7 Group Discussions. June 1982. British American Tobacco Records Collection. Bates No. 102686774102686822. <https://www.industrydocuments.ucsf.edu/tobacco/docs/#id=ktll0200>.
Crocker EC. Measuring food flavors. Journal of Food Science 1937;2(3):273–86.
Cubbin C, Soobader MJ, LeClere FB. The intersection of gender and race/ethnicity in smoking behaviors among menthol and non-menthol smokers in the United States. Addiction 2010;105(Suppl 1):32–8.21059134
Cummings KM, Morley CP, Horan JK, Steger C, Leavell NR. Marketing to America’s youth: evidence from corporate documents. Tobacco Control 2002;11(Suppl 1):15–7.
Dahl M, Erickson RP, Simon SA. Neural responses to bitter compounds in rats. Brain Research 1997;756(1–2):22–34.9187310
Dai H, Hao J. Flavored tobacco use among U.S. adults by age group: 2013–2014. Substance Use & Misuse 2019;54(2):315–23.30380969
Dauphinee AL, Doxey JR, Schleicher NC, Fortmann SP, Henriksen L. Racial differences in cigarette brand recognition and impact on youth smoking. BMC Public Health 2013;13(1):170.23442215
Daylor FL. Accomplishments of 1981 [Inter-office memorandum to Mr. L.F. Meyer]. January 18, 1982. Philip Morris Records Collection. Bates No. 1003656329-1003656335. <https://www.industrydocuments.ucsf.edu/docs/xyjx0112>.
de Oliveira DN, de Menezes M, Catharino RR. Thermal degradation of sucralose: a combination of analytical methods to determine stability and chlorinated byproducts. Scientific Reports 2015;5:9598.25873245
Deering-Rice CE, Shapiro D, Romero EG, Stockmann C, Bevans TS, Phan QM, Stone BL, Fassl B, Nkoy F, Uchida DA, . Activation of transient receptor potential ankyrin-1 by insoluble particulate material and association with asthma. American Journal of Respiratory Cell and Molecular Biology 2015;53(6):893–901.26039217
Delnevo CD, Giovenco DP, Miller Lo EJ. Changes in the mass-merchandise cigar market since the Tobacco Control Act. Tobacco Regulatory Science 2017; 3(2 Suppl 1):S8–S16.28317004
Delnevo CD, Giovenco DP, Villanti AC. Impact of menthol capsule cigarettes on menthol and non-menthol cigarette consumption in the U.S.A., 2008–2020. Tobacco Control 2022.
Delnevo CD, Hrywna M. “A whole ’nother smoke” or a cigarette in disguise: how RJ Reynolds reframed the image of little cigars. American Journal of Public Health 2007;97(8):1368–75.17600253
Delnevo CD, Hrywna M. Clove cigar sales following the U.S. flavoured cigarette ban. Tobacco Control 2015;24(e4):e246–e250.24652459
Delnevo CD, Hrywna M, Miller Lo EJ, Wackowski OA. Examining market trends in smokeless tobacco sales in the United States: 2011–2019. Nicotine & Tobacco Research 2021a;23(8):1420–4.33241271
Delnevo CD, Miller Lo E, Giovenco DP, Cornacchione Ross J, Hrywna M, Strasser AA. Cigar sales in convenience stores in the U.S., 2009–2020. JAMA: the Journal of the American Medical Association 2021b;326(23):2429–32.34932088
Delnevo CD, Wackowski OA, Giovenco DP, Manderski MT, Hrywna M, Ling PM. Examining market trends in the United States smokeless tobacco use: 2005–2011. Tobacco Control 2014;23(2):107–12.23117999
Deutch MR, Grimm D, Wehland M, Infanger M, Kruger M. Bioactive candy: effects of licorice on the cardiovascular system. Foods 2019;8(10):495.31615045
Devos FC, Boonen B, Alpizar YA, Maes T, Hox V, Seys S, Pollaris L, Liston A, Nemery B, Talavera K, . Neuro-immune interactions in chemical-induced airway hyperreactivity. European Respiratory Journal 2016;48(2):380–92.27126687
Dhaka A, Murray AN, Mathur J, Earley TJ, Petrus MJ, Patapoutian A. TRPM8 is required for cold sensation in mice. Neuron 2007;54(3):371–8.17481391
Dionísio A, Molina G, Carvalho D, Santos R, Bicas J, Pastore G. Natural flavourings from biotechnology for foods and beverages. In: Baines D, Seal R, editors. Natural Food Additives, Ingredients and Flavourings. Cambridge (UK): Woodhead Publishing, 2012:231–59.
Dong S, Liu G, Hu J, Zheng M. Polychlorinated dibenzo-p-dioxins and dibenzofurans formed from sucralose at high temperatures. Scientific Reports 2013;3:2946.24126490
Dong X, Han S, Zylka MJ, Simon MI, Anderson DJ. A diverse family of GPCRs expressed in specific subsets of nociceptive sensory neurons. Cell 2001;106(5):619–32.11551509
Drewnowski A. Taste preferences and food intake. Annual Review of Nutrition 1997;17:237–53.
Drgon T, Zhang PW, Johnson C, Walther D, Hess J, Nino M, Uhl GR. Genome wide association for addiction: replicated results and comparisons of two analytic approaches. PLoS One 2010;5(1):e8832.20098672
Duell AK, McWhirter KJ, Korzun T, Strongin RM, Peyton DH. Sucralose-enhanced degradation of electronic cigarette liquids during vaping. Chemical Research in Toxicology 2019;32(6):1241–9.31079450
Duello TM, Rivedal S, Wickland C, Weller A. Race and genetics versus ‘race’ in genetics: a systematic review of the use of African ancestry in genetic studies. Evolution, Medicine, and Public Health 2021;9(1):232–45.34815885
Duffy VB, Glennon S-G, Larsen BA, Rawal S, Oncken C, Litt MD. Heightened olfactory dysfunction and oral irritation among chronic smokers and heightened propylthiouracil (PROP) bitterness among menthol smokers. Physiology & Behavior 2019;201:111–22.30557565
Dussor G, Cao YQ. TRPM8 and migraine. Headache 2016;56(9):1406–17.27634619
Dussor G, Yan J, Xie JY, Ossipov MH, Dodick DW, Porreca F. Targeting TRP channels for novel migraine therapeutics. ACS Chemical Neuroscience 2014;5(11):1085–96.25138211
EC Blend. Flavorartists—liquid sweetener—sucralose, n.d.; <https://www.ecblendflavors.com/flavorartists-liquid-sweetener-sucralose/>; accessed: June 6, 2022.
Eccles R. Menthol and related cooling compounds. Journal of Pharmacy and Pharmacology 1994;46(8):618–30.7529306
Emond JA, Soneji S, Brunette MF, Sargent JD. Flavour capsule cigarette use among U.S. adult cigarette smokers. Tobacco Control 2018;27(6):650–5.29363609
Emura M, Matsuda H. A green and sustainable approach: celebrating the 30th anniversary of the asymmetric l-menthol process. Chemistry & Biodiversity 2014;11(11):1688–99.25408318
Enoch MA, Harris CR, Goldman D. Does a reduced sensitivity to bitter taste increase the risk of becoming nicotine addicted? Addictive Behaviors 2001;26(3):399–404.11436931
Erythropel HC, Kong G, deWinter TM, O’Malley SS, Jordt SE, Anastas PT, Zimmerman JB. Presence of high-intensity sweeteners in popular cigarillos of varying flavor profiles. JAMA: the Journal of the American Medical Association 2018;320(13):1380–3.30285168
Escalera J, von Hehn CA, Bessac BF, Sivula M, Jordt SE. TRPA1 mediates the noxious effects of natural sesquiterpene deterrents. Journal of Biological Chemistry 2008;283(35):24136–44.18550530
European Chemicals Agency. Chapter R.8: Characterisation of dose [concentration]-response for human health. In: Guidance on Information Requirements and Chemical Safety Assessment, 2012; <https://echa.europa.eu/documents/10162/17224/information_requirements_r8_en.pdf/e153243a-03f0-44c5-8808-88af66223258>; accessed: February 14, 2024.
Fagan P, Pokhrel P, Herzog TA, Moolchan ET, Cassel KD, Franke AA, Li X, Pagano I, Trinidad DR, Sakuma KK, . Sugar and aldehyde content in flavored electronic cigarette liquids. Nicotine & Tobacco Research 2018;20(8):985–92.29182761
Fait BW, Thompson DC, Mose TN, Jatlow P, Jordt SE, Picciotto MR, Mineur YS. Menthol disrupts nicotine’s psychostimulant properties in an age and sex-dependent manner in C57BL/6J mice. Behavioural Brain Research 2017;334:72–7.28743602
Fallin A, Goodin AJ, King BA. Menthol cigarette smoking among lesbian, gay, bisexual, and transgender adults. American Journal of Preventive Medicine 2015;48(1):93–7.25245795
Family Smoking Prevention and Tobacco Control Act, Public Law 111–31, 123 U.S. Statutes at Large 1776 (2009).
Fan L, Balakrishna S, Jabba SV, Bonner PE, Taylor SR, Picciotto MR, Jordt SE. Menthol decreases oral nicotine aversion in C57BL/6 mice through a TRPM8-dependent mechanism. Tobacco Control 2016;25 (Suppl 2):ii50–ii54.27698211
Fan X, Wang J, Fan W, Chen L, Gui B, Tan G, Zhou J. Replication of migraine GWAS susceptibility loci in Chinese Han population. Headache 2014;54(4):709–15.24666033
Federal Register. U.S. Department of Health and Human Services, Food and Drug Administration. Deeming tobacco products to be subject to the Federal Food, Drug, and Cosmetic Act, as amended by the Family Smoking Prevention and Tobacco Control Act; restrictions on the sale and distribution of tobacco products and required warning statements for tobacco products, 81 Fed. Reg. 28973 (2016); <https://www.federalregister.gov/d/2016-10685>; accessed: February 19, 2019.
Federal Register. U.S. Food and Drug Administration. Regulation of flavors in tobacco products, 83 Fed. Reg. 12294 (2018).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Content and format of substantial equivalence reports; Food and Drug Administration actions on substantial equivalence reports, final rule (21 CFR Parts 16 and 1107), 86 Fed. Reg. 55224 (2021).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Tobacco product standard for menthol in cigarettes (proposed product standard) (21 CFR 1162), 87 Fed. Reg. 26454 (2022a).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Tobacco Product Standard for Characterizing Flavors in Cigars (proposed product standard) (21 CFR 1166), 87 Fed. Reg. 26396 (2022b).
Federal Trade Commission. Federal Trade Commission Smokeless Tobacco Report for 2020, 2021; <https://www.ftc.gov/system/files/documents/reports/federal-trade-commission-cigarette-report-2020-smokeless-tobacco-report-2020/p114508fy20smokelesstobacco.pdf>; accessed: June 6, 2022.
Ferris KK, Kaplan AR. Application for Research Grant Examination of the Extent of, and Constitutional Basis for, Correlations Between the Following: (1) Taste Thresholds for Quinine and 6-N-Propylthiouracil; (2) Constitutional Predisposition to Pathological Variables; (3) Individual Differences in Smoking Practices and Food Dislikes. July 26, 1962. Council for Tobacco Research Records Collection. Bates No. 50028597-50028602. <https://www.industrydocments.ucsf.edu/docs/sshx0216>.
Fischer R, Griffin F, Kaplan AR. Taste thresholds, cigarette smoking, and food dislikes. Medicina Experimentalis. International Journal of Experimental Medicine 1963;9:151–67.14083335
Flavor and Extract Manufacturers Association. The safety assessment and regulatory authority to use flavors—focus on e-cigarettes, March 3, 2015; <https://www.femaflavor.org/sites/default/files/FEMAGRAS_Ecig_March_3_2015.pdf>; accessed: September 17, 2020.
Flavor and Extract Manufacturers Association. Safety assessment and regulatory authority to use flavors—focus on electronic nicotine delivery systems and flavored tobacco products, September 26, 2016; <https://www.femaflavor.org/sites/default/files/FEMAGRAS%20Ecig%20092616.pdf>; accessed: July 3, 2023.
Flavor and Extract Manufacturers Association. Safety and regulatory authority to use flavors—focus on vaping products, March 2020; <https://www.femaflavor.org/safety-regulatory-authority-use-flavors-focus-vaping-products>; accessed: September 17, 2020.
Flavor and Extract Manufacturers Association. FEMA GRAS, n.d.a; <https://www.femaflavor.org/fema-gras>; accessed: September 16, 2020.
Flavor and Extract Manufacturers Association. Flavor ingredient library, n.d.b; <http://www.femaflavor.org/flavor-library>; accessed: September 23, 2022.
Flavor Jungle. Sweetener (sucralose) solution, n.d.; <https://flavorjungle.com/products/sweetener-sucralose?variant=17267053854778>; accessed: June 6, 2022.
Food Additives Amendment of 1958, Public Law 85–929, 72 Statutes at Large 1784 (1958).
Food and Agricultural Organization of the United Nations. Online edition: “specifications for flavourings”, n.d.; <https://www.fao.org/food/food-safety-quality/scientific-advice/jecfa/jecfa-flav/en/>; accessed: July 8, 2023.
Fox AL. The relationship between chemical constitution and taste. Proceedings of the National Academy of Sciences of the United States of America 1932;18(1):115–20.16577421
Freilinger T, Anttila V, de Vries B, Malik R, Kallela M, Terwindt GM, Pozo-Rosich P, Winsvold B, Nyholt DR, van Oosterhout WP, . Genome-wide association analysis identifies susceptibility loci for migraine without aura. Nature Genetics 2012;44(7):777–82.22683712
Galeotti N, Di Cesare Mannelli L, Mazzanti G, Bartolini A, Ghelardini C. Menthol: a natural analgesic compound. Neuroscience Letters 2002;322(3):145–8.11897159
Gallo V, Dijk FN, Holloway JW, Ring SM, Koppelman GH, Postma DS, Strachan DP, Granell R, de Jongste JC, Jaddoe VW, . TRPA1 gene polymorphisms and childhood asthma. Pediatric Allergy and Immunology 2017;28(2):191–8.27779810
Gammon DG, Rogers T, Coats EM, Nonnemaker JM, Marynak KL, Kuiper NM, King BA. National and state patterns of concept-flavoured cigar sales, USA, 2012–2016. Tobacco Control 2019;28(4):394–400.30068564
Ganz O, King JL, Giovenco DP, Hrywna M, Strasser AA, Delnevo CD. Associations between Black and Mild cigar pack size and demographics and tobacco use behaviors among U.S. adults. International Journal of Environmental Research and Public Health 2021;18(12):6628.34202992
Gardiner PS. The African Americanization of menthol cigarette use in the United States. Nicotine & Tobacco Research 2004;6(Suppl 1):S55–S65.14982709
Gentzke AS, Wang TW, Cornelius M, Park-Lee E, Ren C, Sawdey MD, Cullen KA, Loretan C, Jamal A, Homa DM. Tobacco product use and associated factors among middle and high school students—National Youth Tobacco Survey, United States, 2021. Morbidity and Mortality Weekly Report Surveillance Summaries 2022;71(5):1–29.
Gentzke AS, Wang TW, Jamal A, Park-Lee E, Ren C, Cullen KA, Neff L. Tobacco product use among middle and high school students—United States, 2020. Morbidity and Mortality Weekly Report 2020;69(50):1881–8.33332300
German Federal Office of Justice. Ordinances on tobacco products and related products: prohibited additives in tobacco products, 2017; <http://www.gesetze-im-internet.de/tabakerzv/anlage_1.html>; accessed: July 13, 2023.
Ghosh A, Beyazcicek O, Davis ES, Onyenwoke RU, Tarran R. Cellular effects of nicotine salt-containing e-liquids. Journal of Applied Toxicology 2021;41(3):493–505.33034066
Ghosh A, Nethery RC, Herring AH, Tarran R. Flavored little cigar smoke induces cytotoxicity and apoptosis in airway epithelia. Cell Death Discovery 2017;3:17019.28496992
Ghosh J, Pradhan S, Mittal B. Genome-wide-associated variants in migraine susceptibility: a replication study from North India. Headache 2013;53(10):1583–94.24266335
Gibson C, Jung K. Historical census statistics on population totals by race, 1790 to 1990, and by Hispanic origin, 1970 to 1990, for the United States, regions, divisions, and states, September 2002; <https://www.census.gov/content/dam/Census/library/working-papers/2002/demo/POP-twps0056.pdf>; accessed: July 26, 2023.
Giovenco DP, Miller Lo EJ, Lewis MJ, Delnevo CD. “They’re pretty much made for blunts”: product features that facilitate marijuana use among young adult cigarillo users in the united states. Nicotine & Tobacco Research 2017;19(11):1359–64.27613943
Giovenco DP, Spillane TE, Mauro CM, Martins SS. Cigarillo sales in legalized marijuana markets in the U.S. Drug and Alcohol Dependence 2018;185:347–50.29500953
Giovino GA, Villanti AC, Mowery PD, Sevilimedu V, Niaura RS, Vallone DM, Abrams DB. Differential trends in cigarette smoking in the U.S.A.: is menthol slowing progress? Tobacco Control 2015;24(1):28–37.23997070
Givaudan. Senior tobacco flavourist, n.d.; <https://jobs.givaudan.com/job/Bogor-Senior-Tobacco-Flavourist/494069501>; accessed: March 17, 2020.^*^
Govind AP, Vezina P, Green WN. Nicotine-induced upregulation of nicotinic receptors: underlying mechanisms and relevance to nicotine addiction. Biochemical Pharmacology 2009;78(7):756–65.19540212
Green BG, Schullery MT. Stimulation of bitterness by capsaicin and menthol: differences between lingual areas innervated by the glossopharyngeal and chorda tympani nerves. Chemical Senses 2003;28(1):45–55.12502523
Gu Q, Ni D, Lee LY. Expression of neuronal nicotinic acetylcholine receptors in rat vagal pulmonary sensory neurons. Respiratory Physiology & Neurobiology 2008;161(1):87–91.18206429
Gundle KR, Dingel MJ, Koenig BA. ‘To prove this is the industry’s best hope’: big tobacco’s support of research on the genetics of nicotine addiction. Addiction 2010;105(6):974–83.20659058
Gusain P, Ohki S, Hoshino K, Tsujino Y, Shimokawa N, Takagi M. Chirality-dependent interaction of d- and L-menthol with biomembrane models. Membranes (Basel) 2017;7(4):69.29244740
Ha MA, Smith GJ, Cichocki JA, Fan L, Liu YS, Caceres AI, Jordt SE, Morris JB. Menthol attenuates respiratory irritation and elevates blood cotinine in cigarette smoke exposed mice. PLoS One 2015;10(2):e0117128.25679525
Hajinejad M, Ghaddaripouri M, Dabzadeh M, Forouzanfar F, Sahab-Negah S. Natural cinnamaldehyde and its derivatives ameliorate neuroinflammatory pathways in neurodegenerative diseases. Biomed Research International 2020;14;2020:1034325.
Hamad SH, Johnson NM, Tefft ME, Brinkman MC, Gordon SM, Clark PI, Buehler SS. Little cigars vs 3R4F cigarette: physical properties and HPHC yields. Tobacco Regulatory Science 2017;3(4):459–78.29911130
Hans M, Wilhelm M, Swandulla D. Menthol suppresses nicotinic acetylcholine receptor functioning in sensory neurons via allosteric modulation. Chemical Senses 2012;37(5):463–9.22281529
Hardie L, McCool J, Freeman B. Online retail promotion of e-cigarettes in New Zealand: a content analysis of e-cigarette retailers in a regulatory void. Health Promotion Journal of Australia 2022;33(1):91–8.33565666
Harris B. Menthol: a review of its thermoreceptor interactions and their therapeutic applications. International Journal of Aromatherapy 2006;16(3–4):117–31.
Harrison E, Biswas L, Avusula R, Zhang M, Gong Y, Liu X. Effects of menthol and its interaction with nicotine-conditioned cue on nicotine-seeking behavior in rats. Psychopharmacology 2017;234(23–24):3443–53.28918457
Hassan N, Ahad A, Ali M, Ali J. Chemical permeation enhancers for transbuccal drug delivery. Expert Opinion on Drug Delivery 2010;7(1):97–112.20017661
Havermans A, Krüsemann EJZ, Pennings J, de Graaf K, Boesveldt S, Talhout R. Nearly 20 000 e-liquids and 250 unique flavour descriptions: an overview of the Dutch market based on information from manufacturers. Tobacco Control 2021;30(1):57–62.31685584
He KY, Ge D, He MM. Big data analytics for genomic medicine. International Journal of Molecular Sciences 2017;18(2):412.28212287
Hellman G, Guy T. Gene Expression Profiling Methods Development Study: Assessment of Profiles Obtained from Peripheral Blood—Comparisons of non-Smokers, Full Flavor/Full Flavor Low ‘Tar’ Smokers, and Eclipse Smokers (Proposal #0207). July 25, 2002. R.J. Reynolds Records Collection. Bates No. 550243801-550243803. <https://www.industrydocuments.ucsf.edu/tobacco/docs/#id=tmyx0225>.
Henderson BJ, Grant S, Chu BW, Shahoei R, Huard SM, Saladi SSM, Tajkhorshid E, Dougherty DA, Lester HA. Menthol stereoisomers exhibit different effects on alpha4beta2 nAChR upregulation and dopamine neuron spontaneous firing. eNeuro 2018;5(6).
Henderson BJ, Wall TR, Henley BM, Kim CH, McKinney S, Lester HA. Menthol enhances nicotine reward-related behavior by potentiating nicotine-induced changes in nAChR function, nAChR upregulation, and DA neuron excitability. Neuropsychopharmacology 2017;42(12):2285–91.28401925
Henderson BJ, Wall TR, Henley BM, Kim CH, Nichols WA, Moaddel R, Xiao C, Lester HA. Menthol alone upregulates midbrain nAChRs, alters nAChR subtype stoichiometry, alters dopamine neuron firing frequency, and prevents nicotine reward. Journal of Neuroscience 2016;36(10):2957–74.26961950
Hind JF. Cool Without Menthol Concept. December 19, 1972. R.J. Reynolds Records Collection. Bates No. 501165960. <https://www.industrydocumentslibrary.ucsf.edu/tobacco/docs/mtfx0091>.
Hinds JT 3rd, Li X, Loukas A, Pasch KE, Perry CL. Flavored cigars appeal to younger, female, and racial/ethnic minority college students. Nicotine & Tobacco Research 2018;20(3):347–54.28199700
Hocking MB. Vanillin: synthetic flavoring from spent sulfite liquor. Journal of Chemical Education 1997;74(9):1055.
Hoek J, Gendall P, Eckert C, Louviere J, Blank ML, Thrasher JF. Young adult susceptible non-smokers’ and smokers’ responses to capsule cigarettes. Tobacco Control 2019;28(5):498–505.30282774
Hoffman AC, Salgado RV, Dresler C, Faller RW, Bartlett C. Flavour preferences in youth versus adults: a review. Tobacco Control 2016;25(Suppl 2):ii32–ii39.27633764
Hopp R. Menthol: Its Origins, Chemistry, Physiology and Toxicological Properties. Haarmann + Reimer GmbH Corporate Research 1989. Lorillard Records Collection. Bates No. 07315600-07315622. <https://www.industrydocumentslibrary.ucsf.edu/tobacco/docs/yrfn0034>.
Hox V, Vanoirbeek JA, Alpizar YA, Voedisch S, Callebaut I, Bobic S, Sharify A, De Vooght V, Van Gerven L, Devos F, . Crucial role of transient receptor potential ankyrin 1 and mast cells in induction of non-allergic airway hyperreactivity in mice. American Journal of Respiratory and Critical Care Medicine 2013;187(5):486–93.23262517
Hu XS, Matsunami H. High-throughput odorant receptor deorphanization via phospho-S6 ribosomal protein immunoprecipitation and mRNA Profiling. Methods in Molecular Biology 2018;1820:95–112.29884940
Huang D, Li S, Dhaka A, Story GM, Cao YQ. Expression of the transient receptor potential channels TRPV1, TRPA1 and TRPM8 in mouse trigeminal primary afferent neurons innervating the dura. Molecular Pain 2012;8:66.22971321
IMARC Group. Menthol Cigarette Market: Global Industry Trends, Share, Size, Growth, Opportunity and Forecast 2021–2026, 2020; <https://www.imarcgroup.com/menthol-cigarette-market>; accessed: June 2, 2022.
International Flavors and Fragrances. Snapshot, n.d.; <https://ir.iff.com/financial-information/fundamentals/snapshot>; accessed: August 23, 2023.
Jabba SV, Erythropel HC, Torres DG, Delgado LA, Woodrow JG, Anastas PT, Zimmerman JB, Jordt SE. Synthetic cooling agents in U.S.-marketed e-cigarette refill liquids and popular disposable e-cigarettes: chemical analysis and risk assessment. Nicotine &Tobacco Research 2022;24(7):1037–46.35167696
Jabba SV, Erythropel HC, Woodrow JG, Anastas PT, O’Malley SS, Krishnan-Sarin S, Zimmerman JB, Jordt SE. Synthetic cooling agent in oral nicotine pouch products marketed as “flavor-ban approved”. bioRxiv 2023.
Jackson A, Green B, Erythropel HC, Kong G, Cavallo DA, Eid T, Gueorguieva R, Buta E, O’Malley SS, Krishnan-Sarin S. Influence of menthol and green apple e-liquids containing different nicotine concentrations among youth e-cigarette users. Experimental and Clinical Psychopharmacology 2021;29(4):355–65.32297782
Jiang Y, Gong NN, Hu XS, Ni MJ, Pasi R, Matsunami H. Molecular profiling of activated olfactory neurons identifies odorant receptors for odors in vivo. Nature Neuroscience 2015;18(10):1446–54.26322927
Jo CL, Williams RS, Ribisl KM. Tobacco products sold by internet vendors following restrictions on flavors and light descriptors. Nicotine & Tobacco Research 2015;17(3):344–9.25173777
Jones MR, Apelberg BJ, Tellez-Plaza M, Samet JM, Navas-Acien A. Menthol cigarettes, race/ethnicity, and biomarkers of tobacco use in U.S. adults: the 1999–2010 National Health and Nutrition Examination Survey (NHANES). Cancer Epidemiology, Biomarkers & Prevention 2013;22(2):224–32.
Jones N, Marks R, Ramirez R, Ríos-Vargus M. 2020 Census illuminates racial and ethnic composition of the country, August 12, 2021; <https://www.census.gov/library/stories/2021/08/improved-race-ethnicity-measures-reveal-united-states-population-much-more-multiracial.html>; accessed: November 30, 2022.
Jorde LB, Wooding SP. Genetic variation, classification and ‘race’. Nature Genetics 2004;36(11 Suppl):S28–S33.15508000
Juentgen F, Tutte-Olm DL. Synthetic Menthol From Haarmann & Reimer. July 9, 1996. R.J. Reynolds Records Collection. Bates No. 528443441. <https://www.industrydocumentslibrary.ucsf.edu/tobacco/docs/pkcy0225>.
Kaelberer MM, Caceres AI, Jordt SE. Activation of a nerve injury transcriptional signature in airway-innervating sensory neurons after lipopolysaccharide-induced lung inflammation. American Journal of Physiology: Lung Cellular and Molecular Physiology 2020;318(5):L953–L964.32159971
Kahnert S, Pötschke-Langer M, Schunk S, Nair U, Schaller K. Menthol Capsules in Cigarette Filters—Increasing the Attractiveness of a Harmful Product, Red Series—Tobacco Prevention and Tobacco Control, 2012; <https://www.dkfz.de/de/tabakkontrolle/download/Publikationen/RoteReihe/Band_17_Menthol_Capsules_in_Cigarette_Filters_en.pdf>; accessed: October 31, 2018.
Kale YS, Vibhute N, Belgaumi U, Kadashetti V, Bommanavar S, Kamate W. Effect of using tobacco on taste perception. Journal of Family Medicine and Primary Care 2019;8(8):2699–702.
Kamatou GPP, Vermaak I, Viljoen AM, Lawrence BM. Menthol: a simple monoterpene with remarkable biological properties. Phytochemistry 2013;96:15–25.24054028
Kaplan AR. Progress Report No. 2: Examination of the Extent of, and Constitutional Basis for, Correlations Between the Following: (1) Taste Threshold for Quinine and 6-N-Propylthiouracil; (2) Constitutional Predisposition to Pathological Variables; (3) Individual Differences in Smoking Practices and Food Dislikes. August 7, 1963. Council for Tobacco Research Records Collection. Bates No. 50028102-50028109. <https://www.industrydocuments.ucsf.edu/tobacco/docs/#id=fxhx0216>.
Kaplan AR, Glanville EV, Fischer R. Taste thresholds for bitterness and cigarette smoking. Nature 1964;202:1366.14210998
Kearsley MW, Deis RC. Chapter 13: sorbitol and mannitol. In: Mitchell H, editor. Sweeteners and Sugar Alternatives in Food Technology. 1st ed. Oxford (United Kingdom): Blackwell Publishing, 2006:249–61.
Keithly L, Ferris Wayne G, Cullen DM, Connolly GN. Industry research on the use and effects of levulinic acid: a case study in cigarette additives. Nicotine & Tobacco Research 2005;7(5):761–71.16191747
Khan AM, Narayanan VS, Puttabuddi JH, Chengappa R, Ambaldhage VK, Naik P, Raheel SA. Comparison of taste threshold in smokers and non-smokers using electrogustometry and fungiform papillae count: a case control study. Journal of Clinical and Diagnostic Research 2016;10(5):ZC101–ZC105.27437340
Kichko TI, Kobal G, Reeh PW. Cigarette smoke has sensory effects through nicotinic and TRPA1 but not TRPV1 receptors on the isolated mouse trachea and larynx. American Journal of Physiology: Lung Cellular and Molecular Physiology 2015;309(8):L812–L820.26472811
Kichko TI, Lennerz J, Eberhardt M, Babes RM, Neuhuber W, Kobal G, Reeh PW. Bimodal concentration-response of nicotine involves the nicotinic acetylcholine receptor, transient receptor potential vanilloid type 1, and transient receptor potential ankyrin 1 channels in mouse trachea and sensory neurons. Journal of Pharmacology and Experimental Therapeutics 2013;347(2):529–39.23926288
Kim HS, Pack EC, Koo YJ, Lee YJ, Sung DK, Lee SH, Kim YS, Kwon KH, Lim KM, Jang DY, . Quantitative analysis of menthol and identification of other flavoring ingredients in capsule cigarettes marketed in Korea. Regulatory Toxicology and Pharmacology 2018;92:420–8.29309808
King BA. Flavors are a major driver of the youth e-cigarette epidemic. American Journal of Public Health 2020;110(6):773–4. [See also erratum in American Journal of Public Health 2021;111(2):e6.]32374696
King BA. Flavors remain a major driver of youth e-cigarette use [editorial]. American Journal of Public Health 2022;112(7):999–1000.35617659
King BA, Gammon DG, Marynak KL, Rogers T. Electronic cigarette sales in the United States, 2013–2017. JAMA: the Journal of the American Medical Association 2018;320(13):1379–80.30285167
Klausner K. Menthol cigarettes and smoking initiation: a tobacco industry perspective. Tobacco Control 2011;20(Suppl 2):ii12–ii19.21504927
Kodal JB, Colak Y, Kobylecki CJ, Vedel-Krogh S, Nordestgaard BG, Afzal S. Smoking reduces plasma bilirubin: observational and genetic analyses in the Copenhagen General Population Study. Nicotine & Tobacco Research 2020;22(1):104–10.30202916
Kong G, Bold KW, Simon P, Camenga DR, Cavallo DA, Krishnan-Sarin S. Reasons for cigarillo initiation and cigarillo manipulation methods among adolescents. Tobacco Regulatory Science 2017;32(Suppl 1): S48–S58.
Kong G, Cavallo DA, Goldberg A, LaVallee H, Krishnan-Sarin S. Blunt use among adolescents and young adults: informing cigar regulations. Tobacco Regulatory Science 2018;4(5):50–60.
Kostygina G, Glantz SA, Ling PM. Tobacco industry use of flavours to recruit new users of little cigars and cigarillos. Tobacco Control 2016;25(1):66–74.25354674
Kozlitina J, Risso D, Lansu K, Olsen RHJ, Sainz E, Luiselli D, Barik A, Frigerio-Domingues C, Pagani L, Wooding S, . An African-specific haplotype in MRGPRX4 is associated with menthol cigarette smoking. PLoS Genetics 2019;15(2):e1007916.30768591
Krautter GR, Chen PX, Borgerding MF. Consumption patterns and biomarkers of exposure in cigarette smokers switched to Snus, various dissolvable tobacco products, dual use, or tobacco abstinence. Regulatory Toxicology and Pharmacology 2015;71(2):186–97.25549549
Krautwurst D. Human olfactory receptor families and their odorants. Chemistry & Biodiversity 2008;5(6):842–52.18618407
Krautwurst D, Yau KW, Reed RR. Identification of ligands for olfactory receptors by functional expression of a receptor library. Cell 1998;95(7):917–26.9875846
Kremeyer B, Lopera F, Cox JJ, Momin A, Rugiero F, Marsh S, Woods CG, Jones NG, Paterson KJ, Fricker FR, . A gain-of-function mutation in TRPA1 causes familial episodic pain syndrome. Neuron 2010;66(5):671–80.20547126
Kroeze JH, Bartoshuk LM. Bitterness suppression as revealed by split-tongue taste stimulation in humans. Physiology & Behavior 1985;35(5):779–83.4080842
Krüsemann EJ, Cremers JW, Visser WF, Punter PH, Talhout R. The sensory difference threshold of menthol odor in flavored tobacco determined by combining sensory and chemical analysis. Chemical Senses 2017;42(3):233–8.28034900
Krüsemann EJZ, Boesveldt S, de Graaf K, Talhout R. An e-liquid flavor wheel: a shared vocabulary based on systematically reviewing e-liquid flavor classifications in literature. Nicotine & Tobacco Research 2019;21(10):1310–9.29788484
Krüsemann EJZ, Havermans A, Pennings JLA, de Graaf K, Boesveldt S, Talhout R. Comprehensive overview of common e-liquid ingredients and how they can be used to predict an e-liquid’s flavour category. Tobacco Control 2021;30(2):185–91.32041831
Krüsemann EJZ, Pennings JLA, Cremers J, Bakker F, Boesveldt S, Talhout R. GC-MS analysis of e-cigarette refill solutions: A comparison of flavoring composition between flavor categories. Journal of Pharmaceutical and Biomed Analysis 2020;188:113364.
Kuiper NM, Gammon D, Loomis B, Falvey K, Wang TW, King BA, Rogers T. Trends in sales of flavored and menthol tobacco products in the United States during 2011–2015. Nicotine & Tobacco Research 2018;20(6):698–706.28575408
Laude EA, Morice AH, Grattan TJ. The antitussive effects of menthol, camphor and cineole in conscious guineapigs. Pulmonary Pharmacology 1994;7(3):179–84.7827436
Lawrence D, Cadman B, Hoffman AC. Sensory properties of menthol and smoking topography. Tobacco Induced Diseases 2011;9(Suppl 1):S3.21624149
Lawrence D, Rose A, Fagan P, Moolchan ET, Gibson JT, Backinger CL. National patterns and correlates of mentholated cigarette use in the United States. Addiction 2010;105(Suppl 1):13–31.21059133
Lee LY, Gerhardstein DC, Wang AL, Burki NK. Nicotine is responsible for airway irritation evoked by cigarette smoke inhalation in men. Journal of Applied Physiology 1993;75(5):1955–61.8307845
Lee LY, Gu Q, Lin YS. Effect of smoking on cough reflex sensitivity: basic and preclinical studies. Lung 2010;188(Suppl 1):S23–S27.19844757
Lee LY, Morton RF. Hexamethonium aerosol prevents pulmonary reflexes induced by cigarette smoke in dogs. Respiration Physiology 1986;66(3):303–14.2879328
Lee YO, Hebert CJ, Nonnemaker JM, Kim AE. Multiple tobacco product use among adults in the United States: cigarettes, cigars, electronic cigarettes, hookah, smokeless tobacco, and snus. Preventive Medicine 2014;62:14–9.24440684
Leffingwell J. Cooling ingredients and their mechanism of action. In: Barel AO, Paye M, Maibach HI, editors. Handbook of Cosmetic Science and Technology. New York (NY): Informa Healthcare, 2009:661–75.
Leffingwell JC. Wilkinson-Sword “CWM” [Inter-office memorandum to Mr. R.H. Cundiff]. March 5, 1975. R.J. Reynolds Records Collection. Bates No. 511530095–511530099. <https://www.industrydocumentslibrary.ucsf.edu/tobacco/docs/tkjn0089>.
Leffingwell JC. Cool without menthol & cooler than menthol and cooling compounds as insect repellents, June 8, 2018; <http://leffingwell.com/cooler_than_menthol.htm;>; accessed: August 9, 2022.
Leffingwell JC, Rowsell D. Wilkinson Sword cooling compounds: from the beginning to now, Perfumer & Flavorist, 2014; <https://img.perfumerflavorist.com/files/base/allured/all/document/2014/02/pf.PF_39_03_034_10.pdf>; 39:34–44.
Leffingwell JC, Young HJ, Bernasek E. Tobacco flavoring for smoking products. Winston-Salem (NC): R.J. Reynolds Tobacco Company, 1972; <http://www.leffingwell.com/download/TobaccoFlavorBook.pdf>; accessed: June 19, 2020.
Lemon CH, Norris JE, Heldmann BA. The TRPA1 ion channel contributes to sensory-guided avoidance of menthol in mice. eNeuro 2019;6(6).
Leventhal AM, Tackett AP, Whitted L, Jordt SE, Jabba SV. Ice flavours and non-menthol synthetic cooling agents in e-cigarette products: a review. Tobacco Control 2022:tobaccocontrol-2021-057073.
Lisko JG, Stanfill SB, Watson CH. Quantitation of ten flavor compounds in unburned tobacco products. Analytical Methods 2014;6(13):4698–704.26388954
Liu B, Fan L, Balakrishna S, Sui A, Morris JB, Jordt SE. TRPM8 is the principal mediator of menthol-induced analgesia of acute and inflammatory pain. Pain 2013;154(10):2169–77.23820004
Lorillard. Newport “NFL” Basis of Interest. December 10, 1991. Lorillard Records Collection. Bates No. 82794230-82794232. <https://www.industrydocuments.ucsf.edu/docs/qmjv0121>.
Lu X, Chen Z, She J, Hong L. Thermal decomposition of sucralose. Zhongshan Daxue Xuebao/Acta Scientiarum Natralium Universitatis Sunyatseni 2015;54(1):37–40.
Maeda H, Yamada S, Itoh H, Hori Y. A dual catalyst system provides the shortest pathway for L-menthol synthesis. Chemical Communications (Cambridge, England) 2012;48(12):1772–4.22218824
Mangold JE, Payne TJ, Ma JZ, Chen G, Li MD. Bitter taste receptor gene polymorphisms are an important factor in the development of nicotine dependence in African Americans. Journal of Medical Genetics 2008;45(9):578–82.18524836
Mao D, Yasuda RP, Fan H, Wolfe BB, Kellar KJ. Heterogeneity of nicotinic cholinergic receptors in rat superior cervical and nodose Ganglia. Molecular Pharmacology 2006;70(5):1693–9.16882879
Marynak KL, Wang X, Borowiecki M, Kim Y, Tynan MA, Emery S, King BA. Nicotine pouch unit sales in the U.S., 2016–2020. JAMA: the Journal of the American Medical Association 2021;326(6):566–8.34374729
Matsunami H. Functional expression of mammalian odorant receptors. Chemical Senses 2005;30(Suppl 1): i95–i96.15738214
McKemy DD. TRPM8: The cold and menthol receptor. In: Liedtke WB, Heller S, editors. TRP Ion Channel Function in Sensory Transduction and Cellular Signaling Cascades. Boca Raton (FL): CRC Press/Taylor & Francis, 2007.
Mead EL, Duffy V, Oncken C, Litt MD. E-cigarette palatability in smokers as a function of flavorings, nicotine content and propylthiouracil (PROP) taster phenotype. Addictive Behaviors 2019;91:37–44.30470456
Meixiong J, Dong X. Mas-related g protein-coupled receptors and the biology of itch sensation. Annual Review of Genetics 2017;51:103–21.
Meixiong J, Vasavda C, Green D, Zheng Q, Qi L, Kwatra SG, Hamilton JP, Snyder SH, Dong X. Identification of a bilirubin receptor that may mediate a component of cholestatic itch. Elife 2019;8.
Mendiondo MS, Alexander LA, Crawford T. Health profile differences for menthol and non-menthol smokers: findings from the National Health Interview Survey. Addiction 2010;105(Suppl 1):124–140.21059143
Mennella JA, Pepino MY, Reed DR. Genetic and environmental determinants of bitter perception and sweet preferences. Pediatrics 2005;115(2):e216–e222.15687429
Mersha TB, Beck AF. The social, economic, political, and genetic value of race and ethnicity in 2020. Human Genomics 2020;14(1):37.33059745
Miao S, Beach ES, Sommer TJ, Zimmerman JB, Jordt SE. High-intensity sweeteners in alternative tobacco products. Nicotine & Tobacco Research 2016;18(11):2169–73.27217475
Miller Lo EJ, Giovenco DP, Wackowski OA, Harrell MB, Perry CL, Delnevo CD. The cigarette and smokeless tobacco markets in Texas relative to the United States. Tobacco Regulatory Science 2017;3(2):183–91.28345014
Miller Lo EJ, Young WJ, Ganz O, Talbot EM, O’Connor RJ, Delnevo CD. Trends in overall and menthol market shares of leading cigarette brands in the U.S.A.: 2014–2019. International Journal of Environmental Research and Public Health 2022;19(4):2270.35206458
Minaker LM, Ahmed R, Hammond D, Manske S. Flavored tobacco use among Canadian students in grades 9 through 12: prevalence and patterns from the 2010-2011 youth smoking survey. Preventing Chronic Disease 2014;11:E102.24945240
Moghadam SH, Saliaj E, Wettig SD, Dong C, Ivanova MV, Huzil JT, Foldvari M. Effect of chemical permeation enhancers on stratum corneum barrier lipid organizational structure and interferon alpha permeability. Molecular Pharmaceutics 2013;10(6):2248–60.23587061
Moldoveanu S, Kilby K. Identification of cooling agents in aerosols of an e-cigarette from unit mass resolution spectra enhanced to high mass accuracy. Poster presentation at the 62nd ASMS Conference on Mass Spectrometry and Allied Topics; June 15–19, 2014; Baltimore (MD).
Moodie C, Ford A, Dobbie F, Thrasher JF, McKell J, Purves R. The power of product innovation: smokers’ perceptions of capsule cigarettes. Nicotine & Tobacco Research 2018;20(9):1157–60.29059391
Moodie C, Ford A, Mackintosh A, Purves R. Are all cigarettes just the same? Female’s perceptions of slim, coloured, aromatized and capsule cigarettes. Health Education Research 2015;30(1):1–12.25341674
Moodie C, Thrasher JF, Cho YJ, Barnoya J, Chaloupka FJ. Flavour capsule cigarettes continue to experience strong global growth. Tobacco Control 2019;28(5):595–6.30368482
Morris JB, Stanek J, Gianutsos G. Sensory nerve-mediated immediate nasal responses to inspired acrolein. Journal of Applied Physiology 1999;87(5):1877–86.10562632
Morris JB, Wilkie WS, Shusterman DJ. Acute respiratory responses of the mouse to chlorine. Toxicological Sciences 2005;83(2):380–7.15548641
Moser D, Leitner P, Filipek PA, Hussain S, Rainer M, Jakschitz T, Rode BM, Bonn GK. Quantification and cytotoxicity of degradation products (chloropropanols) in sucralose containing e-liquids with propylene glycol and glycerol as base. Toxicology and Applied Pharmacology 2021;430:115727.34543670
Moskowitz HR. The sweetness and pleasantness of sugars. American Journal of Psychology 1971;84(3):387–405.5142585
Mount Sinai–New York. Methyl salicylate overdose, n.d.; <https://www.mountsinai.org/health-library/poison/methyl-salicylate-overdose>; accessed: August 3, 2022.
Mulcahy MJ, Huard SM, Paulo JA, Wang JH, McKinney S, Henderson BJ, Lester HA. Brain region-specific nAChR and associated protein abundance alterations following chronic nicotine and/or menthol exposure. Journal of Proteome Research 2020;19(1):36–48.31657575
Nair B. Final report on the safety assessment of mentha piperita (peppermint) oil, mentha piperita (peppermint) leaf extract, mentha piperita (peppermint) leaf, and mentha piperita (peppermint) leaf water. International Journal of Toxicology 2001;20(Suppl 3):61–73.
Nasim A, Guy MC, Soule EK, Cobb CO, Blank MD, Eissenberg T. Characteristics and patterns of Black & Mild use among African American smokers. Nicotine & Tobacco Research 2016;18(5):842–9.26615202
National Academies of Sciences, Engineering, and Medicine. Using Population Descriptors in Genetics and Genomics Research: A New Framework for an Evolving Field. Washington (DC): The National Academies Press, 2023.
National Cancer Institute. A Socioecological Approach to Addressing Tobacco-Related Health Disparities. Tobacco Control Monograph 22. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2017. NIH Publication No. 17-CA-8035A.
National Cancer Institute. Cigars: Health Effects and Trends. Tobacco Control Monograph 9. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 1998. NIH Pub. No. 98-4302.
National Center for Biotechnology Information. PubChem Database. Eucalyptol, CID=2758, n.d.; <https://pubchem.ncbi.nlm.nih.gov/compound/2758>; accessed: June 19, 2020.
National Human Genome Research Institute. Race, July 1, 2023; <https://www.genome.gov/genetics-glossary/Race>; accessed: July 3, 2023.
National Human Genome Research Institute. Eugenics: its origin and development (1883–present), n.d.; <https://www.genome.gov/about-genomics/educational-resources/timelines/eugenics#:~:text=Eugenics%20is>; accessed: May 18, 2023.
National Library of Medicine. Reference SNP (rs) report: rs13268757, October 2, 2018; <https://www.ncbi.nlm.nih.gov/snp/rs13268757>; accessed: May 30, 2019.
National Library of Medicine. Peppermint. In: Drugs and Lactation Database (LactMed) (update), January 7, 2019; <https://www.ncbi.nlm.nih.gov/books/NBK501851/>; accessed: May 30, 2019.
Nazari S, Rameshrad M, Hosseinzadeh H. Toxicological effects of glycyrrhiza glabra (licorice): a review. Phytotherapy Research 2017;31(11):1635–50.28833680
Newman FS. Memorandum from Philip Morris In-House Counsel (Newman) to Philip Morris In-House Counsel (Holtzman) Providing Legal Advice and Analysis Regarding Content of Draft Press Release for New Product Introduction; Northwind Comments on 3rd Tier Inquiries. May 14, 1981. Philip Morris Records Collection. Bates No. 1005113528-1005113529. <https://www.industrydocuments.ucsf.edu/docs/#id=kgxy0101>.
Nonnemaker J, Hersey J, Homsi G, Busey A, Allen J, Vallone D. Initiation with menthol cigarettes and youth smoking uptake. Addiction 2013;108(1):171–8.22862154
Nude Nicotine. Whole erythritol solution (5%), n.d.; <https://nudenicotine.com/products/wholesale-erythritol-solution-5>; accessed: September 18, 2020.
Oliveira-Maia AJ, Stapleton-Kotloski JR, Lyall V, Phan TH, Mummalaneni S, Melone P, Desimone JA, Nicolelis MA, Simon SA. Nicotine activates TRPM5-dependent and independent taste pathways. Proceedings of the National Academy of Sciences of the United States of America 2009;106(5):1596–601.19164511
Omaiye EE, McWhirter KJ, Luo W, Pankow JF, Talbot P. High-nicotine electronic cigarette products: toxicity of JUUL fluids and aerosols correlates strongly with nicotine and some flavor chemical concentrations. Chemical Research in Toxicology 2019;32(6):1058–69.30896936
Oncken C, Feinn R, Covault J, Duffy V, Dornelas E, Kranzler HR, Sankey HZ. Genetic vulnerability to menthol cigarette preference in women. Nicotine & Tobacco Research 2015;17(12):1416–20.25832883
Osmalov JS. Little Cigar Samples—Reference: My Memo of April 13, 1970 on the Same Subject. April 15, 1970. Philip Morris Records Collection. Bates No. 10002913561000291357. <https://www.industrydocuments.ucsf.edu/docs/#id=ryvk0127>.
Palmatier MI, Smith AL, Odineal EM, Williams EA, Sheppard AB, Bradley CA. Nicotine self-administration with tobacco flavor additives in male rats. Nicotine & Tobacco Research 2020;22(2):224–31.30980717
Pang RD, Goldenson NI, Kirkpatrick M, Barrington-Trimis JL, Cho J, Leventhal AM. Sex differences in the appeal of flavored e-cigarettes among young adult e-cigarette users. Psychology of Addictive Behaviors 2020;34(2):303–7.31961168
Parchem. Cyclohexanecarboxamide; n-ethyl-5-methyl2-(1-methylethyl)-: product description, n.d.; <https://www.parchem.com/chemical-supplier-distributor/CYCLOHEXANECARBOXAMIDE-N-ETHYL-5-METHYL-2-1-METHYLETHYL-020875.aspx>; accessed: June 28, 2023.
Park-Lee E, Ren C, Cooper M, Cornelius M, Jamal A, Cullen KA. Tobacco product use among middle and high school students—United States, 2022. Morbidity and Mortality Weekly Report 2022;71(45):1429–35.36355596
Park-Lee E, Ren C, Sawdey MD, Gentzke AS, Cornelius M, Jamal A, Cullen KA. Notes from the field: e-cigarette use among middle and high school students—National Youth Tobacco Survey, United States, 2021. Morbidity and Mortality Weekly Report 2021;70(39):1387–9.34591834
Pavlos P, Vasilios N, Antonia A, Dimitrios K, Georgios K, Georgios A. Evaluation of young smokers and non-smokers with Electrogustometry and Contact Endoscopy. BMC Ear, Nose, and Throat Disorders 2009;9:9.19695082
Pepino MY. Metabolic effects of non-nutritive sweeteners. Physiology & Behavior 2015;152(Pt B):450–5.26095119
Perkins KA, Karelitz JL, Kunkle N. Evaluation of menthol per se on acute perceptions and behavioral choice of cigarettes differing in nicotine content. Journal of Psychopharmacology 2018;32(3):324–31.29468937
Perkins KA, Kunkle N, Karelitz JL. Threshold dose for behavioral discrimination of cigarette nicotine content in menthol vs. non-menthol smokers. Psychopharmacology 2017;234(8):1255–65.28210778
Pesko MF, Robarts AMT. Adolescent tobacco use in urban versus rural areas of the United States: the influence of tobacco control policy environments. Journal of Adolescent Health 2017;61(1):70–6.
Philip Morris Records Collection. Younger Adult Smoker Opportunity Purpose. 2010. Philip Morris Records Collection. Bates No. 3990679479-3990679744. <https://www.industrydocuments.ucsf.edu/docs/#id=nlmj0191>.
Pithawalla YB. Report on Analysis of Camel Lights “Now With Menthol Boost”. June 29, 2007. Philip Morris Records Collection. Bates No. 30851020363085102046. <https://www.industrydocuments.ucsf.edu/docs/jnwd0226>.
Pletcher MJ, Hulley BJ, Houston T, Kiefe CI, Benowitz N, Sidney S. Menthol cigarettes, smoking cessation, atherosclerosis, and pulmonary function: the Coronary Artery Risk Development in Young Adults (CARDIA) Study. Archives of Internal Medicine 2006;166(17):1915–22.17000950
Proudfoot CJ, Garry EM, Cottrell DF, Rosie R, Anderson H, Robertson DC, Fleetwood-Walker SM, Mitchell R. Analgesia mediated by the TRPM8 cold receptor in chronic neuropathic pain. Current Biology 2006;16(16):1591–605.16920620
PubChem. Explore chemistry [home page], n.d.; <https://pubchem.ncbi.nlm.nih.gov/>; accessed: October 6, 2022.
Public Health Law Center. 11/9/22—Proposition 31 in California passed! Now what?, November 2022; <https://www.publichealthlawcenter.org/commentary/221109/11/9/22-proposition-31-california-passed-now-what>; accessed: July 5, 2023.
Public Health Law Center. Big tobacco creates new “sensation: with same old playbook, April 7, 2023a; <https://www.publichealthlawcenter.org/commentary/230407/4/7/2023-big-tobacco-creates-new-sensation-same-old-playbook>; accessed: June 23, 2023.
Public Health Law Center. U.S. Sales Restrictions on Flavored Tobacco Products, May 2023b; <https://www.publichealthlawcenter.org/sites/default/files/resources/US-sales-restrictions-flavored-tobacco-products.pdf>; accessed: July 3, 2023.
Pure Food and Drug Act of 1906, Public Law 59–384, 34 Statutes at Large 768 (1906).
Qian J, Mummalaneni S, Grider JR, Damaj MI, Lyall V. Nicotinic acetylcholine receptors (nAChRs) are expressed in Trpm5 positive taste receptor cells (TRCs). PLoS One 2018a;13(1):e0190465.29293602
Qian J, Mummalaneni S, Larsen J, Grider JR, Spielman AI, Ozdener MH, Lyall V. Nicotinic acetylcholine receptor (CHRN) expression and function in cultured human adult fungiform (HBO) taste cells. PLoS One 2018b;13(3):e0194089.29513745
QYResearch. Global Menthol Market Research Report 2017, 2017; <https://www.giiresearch.com/report/qyr599315-global-menthol-market-research-report.html>; accessed: October 24, 2018.^*^
R.J. Reynolds. Smoking and Chewing Tobacco Production Tobacco Used. 1976. R.J. Reynolds Records Collection. Bates No. 509302718/2723. <https://www.industrydocuments.ucsf.edu/docs/rmby0097>.
R.J. Reynolds. MBO Evaluation Summary. July 6, 1977. R.J. Reynolds Records Collection. Bates No. 504692166–504692219. <https://www.industrydocumentslibrary.>.
R.J. Reynolds. Part XIII Flavor and Flavor Evaluation. Chapter 47 Flavor Evaluation of Cigarettes. 1987. R.J. Reynolds Records Collection. Bates No. 506523654-506523685. <https://www.industrydocuments.ucsf.edu/docs/jqmw0095>.
R.J. Reynolds Tobacco Company. Commercial integrity—view ingredients by brand, 2023; <https://perma.cc/LR55-2KEJ>; accessed: July 5, 2023.
R.J. Reynolds Tobacco Company. Tobacco product ingredients: general & brand specific ingredients, n.d.; <https://rjrt.com/commercial-integrity/ingredients/>; accessed: July 8, 2023.
Rahn A, Yaylayan VA. Thermal degradation of sucralose and its potential in generating chloropropanols in the presence of glycerol. Food Chemistry 2010;118(1):56–61.
Rao PD, Nanding H, Strasser AA, Wise PM. Pilot experiment: the effect of added flavorants on the taste and pleasantness of mixtures of glycerol and propylene glycol. Chemosensory Perception 2018;11(1):1–9.29755639
Rath JM, Villanti AC, Williams VF, Richardson A, Pearson JL, Vallone DM. Correlates of current menthol cigarette and flavored other tobacco product use among U.S. young adults. Addictive Behaviors 2016;62:35–41.27310032
Regan AK, Dube SR, Arrazola R. Smokeless and flavored tobacco products in the U.S.: 2009 Styles survey results. American Journal of Preventive Medicine 2012;42(1):29–36.22176843
Reger L, Moß J, Hahn H, Hahn J. Analysis of menthol, menthol-like, and other tobacco flavoring compounds in cigarettes and in electrically heated tobacco products. Contributions to Tobacco Research 2018;28(2):93.
Reimer K. Ueber eine neue bildungsweise aromatischer aldehyde. Berichte der Deutschen Chemischen Gesellschaft 1876;9(1):423–4.
Ren L, Chang MJ, Zhang Z, Dhaka A, Guo Z, Cao YQ. Quantitative analysis of mouse dural afferent neurons expressing TRPM8, VGLUT3, and NF200. Headache 2018;58(1):88–101.28925503
Reynolds American. Reynolds files lawsuit in California to protect its lawful non-menthol products [press release], May 11, 2023; <https://www.reynoldsamerican.com/news/reynolds-files-lawsuit-in-california-to-protect-its-lawful-non-menthol-products/>; accessed: July 5, 2023.
Rising J, Alexander L. Marketing of menthol cigarettes and consumer perceptions. Tobacco Induced Diseases 2011;9(Suppl 1):S2.21624148
Risso D, Sainz E, Gutierrez J, Kirchner T, Niaura R, Drayna D. Association of TAS2R38 haplotypes and menthol cigarette preference in an African American cohort. Nicotine & Tobacco Research 2017;19(4):493–4.27733510
Risso DS, Kozlitina J, Sainz E, Gutierrez J, Wooding S, Getachew B, Luiselli D, Berg CJ, Drayna D. Genetic variation in the TAS2R38 bitter taste receptor and smoking behaviors. PLoS One 2016a;11(10):e0164157.27711175
Risso DS, Mezzavilla M, Pagani L, Robino A, Morini G, Tofanelli S, Carrai M, Campa D, Barale R, Caradonna F, et al. Global diversity in the TAS2R38 bitter taste receptor: revisiting a classic evolutionary PROPosal. Scientific Reports 2016b;6:25506.27138342
Roberts ME, Doogan NJ, Stanton CA, Quisenberry AJ, Villanti AC, Gaalema DE, Keith DR, Kurti AN, Lopez AA, Redner R, . Rural versus urban use of traditional and emerging tobacco products in the United States, 2013–2014. American Journal of Public Health 2017;107(10):1554–9.28817323
Rock VJ, Davis SP, Thorne SL, Asman KJ, Caraballo RS. Menthol cigarette use among racial and ethnic groups in the United States, 2004–2008. Nicotine & Tobacco Research 2010;12(Suppl 2):S117–S124.21177368
Roemer E, Dempsey R, Van Overveld FJ, Berges A, Pype J, Weiler H, Vanscheeuwijck P, Schorp MK. Toxicological assessment of kretek cigarettes Part 5: mechanistic investigations, inhalation toxicity. Regulatory Toxicology and Pharmacology 2014;70(Suppl 1):S54–S65.25455231
Rosbrook K, Erythropel HC, DeWinter TM, Falinski M, O’Malley S, Krishnan-Sarin S, Anastas PT, Zimmerman JB, Green BG. The effect of sucralose on flavor sweetness in electronic cigarettes varies between delivery devices. PLoS One 2017;12(10):e0185334.28968411
Rose JE, Behm FM. Extinguishing the rewarding value of smoke cues: pharmacological and behavioral treatments. Nicotine & Tobacco Research 2004;6(3):523–32.15203786
Rose JE, Behm FM, Drgon T, Johnson C, Uhl GR. Personalized smoking cessation: interactions between nicotine dose, dependence and quit-success genotype score. Molecular Medicine 2010;16(7–8):247–53.20379614
Rose SW, Johnson AL, Glasser AM, Villanti AC, Ambrose BK, Conway K, Cummings KM, Stanton CA, Delnevo C, Wackowski OA, . Flavour types used by youth and adult tobacco users in Wave 2 of the Population Assessment of Tobacco and Health (PATH) Study 2014–2015. Tobacco Control 2020;29(4):432–46.31542778
Rossel S. Filter forum, June 1, 2018; <https://tobaccoreporter.com/2018/06/01/filter-forum/>; accessed: August 3, 2022.
Rostron BL, Cheng YC, Gardner LD, Ambrose BK. Prevalence and reasons for use of flavored cigars and ENDS among U.S. youth and adults: estimates from Wave 4 of the PATH Study, 2016–2017. American Journal of Health Behavior 2020;44(1):76–81.31783934
Rowe DJ, editor. Chemistry and Technology of Flavors and Fragrances. Oxford (United Kingdom): Blackwell Publishing, 2005.
Schmitz D, Shubert VA, Betz T, Schnell M. Exploring the conformational landscape of menthol, menthone, and isomenthone: a microwave study. Frontiers in Chemistry 2015;3.
Schröder K, Escher SE, Hoffmann-Dörr S, Kühne R, Simetska N, Mangelsdorf I. Evaluation of route-to-route extrapolation factors based on assessment of repeated dose toxicity studies compiled in the database RepDose®. Toxicology Letters 2016;261:32–40.27553675
Schwab W, Davidovich-Rikanati R, Lewinsohn E. Biosynthesis of plant-derived flavor compounds. Plant Journal 2008;54(4):712–32.
Scott-Sheldon LAJ, Stroud LR. Preferences and perceptions of flavored hookah tobacco among U.S. women. American Journal of Health Behavior 2018;42(3):37–46.29663979
Scott TR, Giza BK, Yan J. Electrophysiological responses to bitter stimuli in primate cortex. Annals of the New York Academy of Sciences 1998;855:498–501.9929646
Sell CS. Chemistry and the Sense of Smell. Hoboken (NJ): John Wiley & Sons, 2014.
Semwal M. From importing menthol mint to becoming a leading exporter, n.d.; <https://www.csir.res.in/csir-success-stories/importing-menthol-mint-becoming-leading-exporter>; accessed: July 3, 2023.
Sherwood CL, Boitano S. Airway epithelial cell exposure to distinct e-cigarette liquid flavorings reveals toxicity thresholds and activation of CFTR by the chocolate flavoring 2,5-dimethypyrazine. Respiratory Research 2016;17(1):57.27184162
Shoeb A, Chowta M, Pallempati G, Rai A, Singh A. Evaluation of antidepressant activity of vanillin in mice. Indian Journal of Pharmacology 2013;45(2):141–4.23716889
Singh S, Kumar S. Potential of Indian menthol mint oil in production and export: a growth and instability analysis. Journal of the Science of Food and Agriculture 2021;12(1):214–19.
Slack JP, Pennimpede JE. Use of a TAS2R7 nucleic acid sequence to identify modulators (United States Patent No. US8557530B2), October 15, 2013; <https://patents.google.com/patent/US8557530B2/en>; accessed: March 19, 2020.
Small DM. Flavor is in the brain. Physiology & Behavior 2012;107(4):540–52.22542991
Smith PH, Akpara E, Haq R, El-Miniawi M, Thompson AB. Gender and menthol cigarette use in the united states: a systematic review of the recent literature (2011–May 2017). Current Addiction Reports 2017;4(4):431–8.29497593
Snyder LH. Inherited Taste Deficiency. Science 1931;74(1910):151–2.17782493
Song SH, Vieille C. Recent advances in the biological production of mannitol. Applied Microbiology and Biotechnology 2009;84(1):55–62.19578847
Soule EK, Sakuma KK, Palafox S, Pokhrel P, Herzog TA, Thompson N, Fagan P. Content analysis of internet marketing strategies used to promote flavored electronic cigarettes. Addictive Behaviors 2019;91:128–35.30606627
Squier CA, Mantz MJ, Wertz PW. Effect of menthol on the penetration of tobacco carcinogens and nicotine across porcine oral mucosa ex vivo. Nicotine & Tobacco Research 2010;12(7):763–7.20511349
Stahre M, Okuyemi KS, Joseph AM, Fu SS. Racial/ethnic differences in menthol cigarette smoking, population quit ratios and utilization of evidence-based tobacco cessation treatments. Addiction 2010;105(Suppl 1):75–83.21059138
Stanfill S, Tran H, Tyx R, Fernandez C, Zhu W, Marynak K, King B, Valentin-Blasini L, Blount BC, Watson C. Characterization of total and unprotonated (free) nicotine content of nicotine pouch products. Nicotine & Tobacco Research 2021;23(9):1590–6.34233354
State of California Department of Justice. California Flavor Ban, Health & Safety Code § 104559.5 Notice of Determination 23-04-A1, 2023; <https://california-healthline.org/wp-content/uploads/sites/3/2023/05/California-Attorney-General-Letters.pdf>; accessed: July 5, 2023.
Stepanov I, Jensen J, Biener L, Bliss RL, Hecht SS, Hatsukami DK. Increased pouch sizes and resulting changes in the amounts of nicotine and tobacco-specific N-nitrosamines in single pouches of Camel Snus and Marlboro Snus. Nicotine & Tobacco Research 2012;14(10):1241–5.22259150
Stepanov I, Jensen J, Hatsukami D, Hecht SS. New and traditional smokeless tobacco: comparison of toxicant and carcinogen levels. Nicotine & Tobacco Research 2008;10(12):1773–82.19023828
Sterling K, Fryer C, Pagano I, Jones D, Fagan P. Association between menthol-flavoured cigarette smoking and flavoured little cigar and cigarillo use among African-American, Hispanic, and white young and middle-aged adult smokers. Tobacco Control 2016a;25(Suppl 2):ii21–ii31.27856997
Sterling KL, Fryer CS, Fagan P. The most natural tobacco used: a qualitative investigation of young adult smokers’ risk perceptions of flavored little cigars and cigarillos. Nicotine & Tobacco Research 2016b;18(5):827–33.26175458
Sterling KL, Fryer CS, Nix M, Fagan P. Appeal and impact of characterizing flavors on young adult small cigar use. Tobacco Regulatory Science 2015;1:42–53.27917396
Sterling KL, Fryer CS, Pagano I, Fagan P. Little cigars and cigarillos use among young adult cigarette smokers in the United States: understanding risk of concomitant use subtypes. Nicotine & Tobacco Research 2016c;18(12):2234–42.27613889
Swedish Match. Swedish Match Results Presentation: Q3 2022, 2022; <https://www.swedishmatch.com/globalassets/documents/presentations/2022_q3_interimpresentation_swedishmatch_en.pdf>; accessed: July 5, 2023.
Sweeney WR, Marcq P, Pierotti J, Thiem D. Sweet cigar (U.S. Patent Application Publication), 2013; <https://patents.google.com/patent/US20130087159>; accessed: September 29, 2020.
Symrise. Simcool Cooling Agents: Infinite Sensations, n.d.; <https://www.symrise.com/fileadmin/symrise/Marketing/Scent_and_care/Aroma_molecules/symrise-symcool-A4-pages-eng.pdf>; accessed: June 6, 2022.
Tackett AP, Barrington-Trimis JL, Leventhal AM. “Flavour ban approved”: new marketing strategies from tobacco-free nicotine pouch maker Zyn. Tobacco Control 2022.
Talhout R, Richter PA, Stepanov I, Watson CV, Watson CH. Cigarette design features: effects on emission levels, user perception, and behavior. Tobacco Regulatory Science 2018;4(1):592–604.29250577
Talley B, Mary Gee R, Allen D, Marshall ES, Encinas K, Lim S. Assessment of smokeless tobacco use in the history and physical examination by primary healthcare providers. Journal of the American Academy of Nurse Practitioners 2011;23(8):443–7.21790838
TBD Liquids. Sweetener—super concentrate, n.d.; <https://www.tbdliquids.com/products/sweetener-additive>; accessed: June 6, 2022.^*^
The Interdepartmental Group on Health Risks from Chemicals. Guidelines on Route-to-Route Extrapolation of Toxicity Data When Assessing Health Risks of Chemicals, 2006; <http://www.iehconsulting.co.uk/IEH_Consulting/IEHCPubs/IGHRC/cr12.pdf>; accessed: February 14, 2024.
The International Genome Sample Resource. IGSR: The International Genome Sample Resource: supporting human variation data, n.d.; <https://www.internationalgenome.org/>; accessed: May 12, 2023.
The Roper Organization. Study of Smoker’s Habits and Attitudes with Special Emphasis on Low Tar and Menthol Cigarettes, Volume I. March 1979. Philip Morris Records Collection. Bates No. 2049455309-2049455318. <https://www.industrydocuments.ucsf.edu/docs/#id=rjmd0125>.
Thrasher JF, Abad-Vivero EN, Moodie C, O’Connor RJ, Hammond D, Cummings KM, Yong HH, Salloum RG, Czoli C, Reynales-Shigematsu LM. Cigarette brands with flavour capsules in the filter: trends in use and brand perceptions among smokers in the USA, Mexico and Australia, 2012-2014. Tobacco Control 2016;25(3):275–83.25918129
Tiemann F, Haarmann W. Ueber das Coniferin und seine umwandlung in das aromatische princip der vanille. Berichte der Deutschen Chemischen Gesellschaft 1874;7(1):608–23.
Tierney PA, Karpinski CD, Brown JE, Luo W, Pankow JF. Flavour chemicals in electronic cigarette fluids. Tobacco Control 2016;25(e1):e10–e15.25877377
Tilley NM. The R.J. Reynolds Tobacco Company. Chapel Hill (NC): University of North Carolina Press, 1985.
Tobacco Industry Research Committee. A Frank Statement to Cigarette Smokers. January 4, 1954. Lorillard Records Collection. Bates No. 86017454. <https://www.industrydocuments.ucsf.edu/tobacco/docs/#id=zkph0129>.
Tomassini S, Cuoghi V, Catalani E, Casini G, Bigiani A. Long-term effects of nicotine on rat fungiform taste buds. Neuroscience 2007;147(3):803–10.17560039
Trapl ES, Koopman Gonzalez SJ, Cofie L, Yoder LD, Frank J, Sterling KL. Cigar product modification among high school youth. Nicotine & Tobacco Research 2018;20(3):370–6.28003508
Trinkets & Trash. Chill & menthol [emailed advertisement], 2021; <https://trinketsandtrash.org/detail.php?artifactid=15520>; accessed: October 6, 2022.
U.S. Department of Health and Human Services. How Tobacco Smoke Causes Disease—The Biology and Behavioral Basis for Smoking-Attributable Disease: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2010.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2012.
U.S. Department of Health and Human Services. E-Cigarette Use Among Youth and Young Adults. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2016.
U.S. Food and Drug Administration. Harmful and potentially harmful constituents in tobacco products and tobacco smoke: established list, April 2012; <https://www.fda.gov/tobacco-products/rules-regulations-and-guidance/harmful-and-potentially-harmful-constituents-tobacco-products-and-tobacco-smoke-established-list>; accessed: July 5, 2023.
U.S. Food and Drug Administration. Preliminary Scientific Evaluation of the Possible Public Health Effects of Menthol Versus Nonmenthol Cigarettes, 2013; <https://www.fda.gov/media/86497/download>; accessed: February 19, 2019.
U.S. Food and Drug Administration. Additional information about high-intensity sweeteners permitted for use in food in the United States, February 8, 2018a; <https://www.fda.gov/food/food-additives-petitions/additional-information-about-high-intensity-sweet-eners-permitted-use-food-united-states>; accessed: March 19, 2020.
U.S. Food and Drug Administration. Federal Food, Drug, and Cosmetic Act (FD&C Act), March 29, 2018b; <https://www.fda.gov/regulatory-information/laws-enforced-fda/federal-food-drug-and-cosmetic-act-fdc-act>; accessed: September 16, 2020.
U.S. Food and Drug Administration. FDA grants first-ever modified risk orders to eight smokeless tobacco products [press release], October 22, 2019; <https://www.fda.gov/news-events/press-announcements/fda-grants-first-ever-modified-risk-orders-eight-smokeless-tobacco-products>; accessed: September 18, 2020.
U.S. Food and Drug Administration. Enforcement priorities for electronic nicotine delivery systems (ENDS) and other deemed products on the market without premarket authorization (revised): guidance for industry, April 2020a; <https://www.fda.gov/regulatory-information/search-fda-guidance-documents/enforcement-priorities-electronic-nicotine-delivery-system-ends-and-other-deemed-products-market>; accessed: July 13, 2023.
U.S. Food and Drug Administration. Family Smoking Prevention and Tobacco Control Act—an overview, June 3, 2020b; <https://www.fda.gov/tobacco-products/rules-regulations-and-guidance/family-smoking-prevention-and-tobacco-control-act-overview#ingredients>; accessed: September 16, 2020.
U.S. Food and Drug Administration. Technical Project Lead (TPL) Review: SE0015280 (Copenhagen long cut special mint), 2020c; <https://www.fda.gov/media/144490/download>; accessed: May 31, 2023.
U.S. Food and Drug Administration. FDA commits to evidence-based actions aimed at saving lives and preventing future generations of smokers [press release], April 29, 2021; <https://www.fda.gov/news-events/press-announcements/fda-commits-evidence-based-actions-aimed-saving-lives-and-preventing-future-generations-smokers>; accessed: June 7, 2021.
U.S. Food and Drug Administration. GRAS notices, July 26, 2023; <https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=GRASNotices>; accessed: July 27, 2023.
U.S. Food and Drug Administration. Premarket tobacco product marketing granted orders, n.d.; <https://www.fda.gov/tobacco-products/premarket-tobacco-product-applications/premarket-tobacco-product-marketing-granted-orders>; accessed: July 10, 2022.
U.S. Government Publishing Office. Title 26: internal revenue code, chapter 52—tobacco products and cigarette papers and tubes (U.S. Code 5701), 2011; <https://www.govinfo.gov/app/details/USCODE-2011-title26/USCODE-2011-title26-subtitleE-chap52>; accessed: September 26, 2022.
Ueno H, Shimada A, Suemitsu S, Murakami S, Kitamura N, Wani K, Takahashi Y, Matsumoto Y, Okamoto M, Fujiwara Y, . Comprehensive behavioral study of the effects of vanillin inhalation in mice. Biomedicine and Pharmacotherapy 2019;115:108879.31035009
Uhl GR, Walther D, Behm FM, Rose JE. Menthol preference among smokers: association with TRPA1 variants. Nicotine & Tobacco Research 2011;13(12):1311–5.21719896
Ulrich CE, Haddock MP, Alarie Y. Airborne chemical irritants. Role of the trigeminal nerve. Archives of Environmental Health 1972;24(1):37–42.5009630
Victor RG, Haley RW, Willett DL, Peshock RM, Vaeth PC, Leonard D, Basit M, Cooper RS, Iannacchione VG, Visscher WA, . The Dallas Heart Study: a population-based probability sample for the multidisciplinary study of ethnic differences in cardiovascular health. American Journal of Cardiology 2004;93(12):1473–80.15194016
Vieira-Alves I, Coimbra-Campos LMC, Sancho M, da Silva RF, Cortes SF, Lemos VS. Role of the α7 nicotinic acetylcholine receptor in the pathophysiology of atherosclerosis. Frontiers in Physiology 2020;11:621769.33424644
Villanti AC, Mowery PD, Delnevo CD, Niaura RS, Abrams DB, Giovino GA. Changes in the prevalence and correlates of menthol cigarette use in the U.S.A., 2004–2014. Tobacco Control 2016;25(Suppl 2):ii14–ii20.27729565
Viso ME. Status Report on the Synthesis of 6-Methanol-2-( 2-Isopropyl-5-Methylcyclohexyloxy) Oxocyclohexane and 5-Hydroxy-6-Methanol-2-( 2-Isopropyl-5-Methylcyclohhexyl-Oxy) Oxocyclohexane, Compounds to Deliver Menthol Flavor in Mentholated Cigarettes (Project B-484, SYN). June 12, 1992. Lorillard Records Collection. Bates No. 87216810–87216816. <https://www.industrydocumentslibrary.ucsf.edu/tobacco/docs/nyph0003>.
Wang M. B&W R&D File Note. Saccharin Determination in Several Competitors’ Wet Snuff Samples. December 3, 1993. Brown & Williamson Records Collection. Bates No. 598000122–598000130. <https://industrydocuments.library.ucsf.edu/tobacco/docs/jljx0138>.
Wang T, Wang B, Chen H. Menthol facilitates the intravenous self-administration of nicotine in rats. Frontiers in Behavioral Neuroscience 2014;8:437.25566005
Wang X, Kim Y, Borowiecki M, Tynan MA, Emery S, King BA. Erratum to: trends in cigar sales and prices, by product and flavor type—the United States, 2016–2020. Nicotine & Tobacco Research 2022a:ntac038.
Wang X, Kim Y, Borowiecki M, Tynan MA, Emery S, King BA. Trends in cigar sales and prices, by product and flavor type—the United States, 2016–2020. Nicotine & Tobacco Research 2022b;24(4):606–11.34792585
Watson HR, Hems R, Rowsell DG, Spring DJ. New compounds with menthol cooling effect. Journal of the Society of Cosmetic Chemists 1978;29(4):185–200.
Wen CP, Zhang F, Liang D, Wen C, Gu J, Skinner H, Chow WH, Ye Y, Pu X, Hildebrandt MA, . The ability of bilirubin in identifying smokers with higher risk of lung cancer: a large cohort study in conjunction with global metabolomic profiling. Clinical Cancer Research 2015;21(1):193–200.25336700
Wickham RJ. The biological impact of menthol on tobacco dependence. Nicotine & Tobacco Research 2020;22(10):1676–84.31867627
Willis DN, Liu B, Ha MA, Jordt SE, Morris JB. Menthol attenuates respiratory irritation responses to multiple cigarette smoke irritants. FASEB Journal 2011;25(12):4434–44.21903934
Wilson SR, Gerhold KA, Bifolck-Fisher A, Liu Q, Patel KN, Dong X, Bautista DM. TRPA1 is required for histamine-independent, Mas-related G protein-coupled receptor-mediated itch. Nature Neuroscience 2011;14(5):595–602.21460831
Wittenberg RE, Wolfman SL, De Biasi M, Dani JA. Nicotinic acetylcholine receptors and nicotine addiction: a brief introduction. Neuropharmacology 2020;177:108256.32738308
Wolfe JM, Kluender KR, Levi DM, editors. Sensation and Perception. 4th ed. Sunderland (MA): Sinauer Associates, Inc., 2014.
Wong SL, Epperson AE, Rogers J, Castro RJ, Jackler RK, Prochaska JJ. A multimodal assessment of tobacco use on a university campus and support for adopting a comprehensive tobacco-free policy. Preventive Medicine 2020;133:106008.32027917
Wooding S. Phenylthiocarbamide: a 75-year adventure in genetics and natural selection. Genetics 2006;172(4):2015–23.16636110
Xu J, Xu H, Liu Y, He H, Li G. Vanillin-induced amelioration of depression-like behaviors in rats by modulating monoamine neurotransmitters in the brain. Psychiatry Research 2015;225(3):509–14.25595338
Xu J, Yang W, Zhang G, Gu Q, Lee LY. Calcium transient evoked by nicotine in isolated rat vagal pulmonary sensory neurons. American Journal of Physiology: Lung Cellular and Molecular Physiology 2007;292(1):L54–L61.16920888
Yerger VB. Menthol’s potential effects on nicotine dependence: a tobacco industry perspective. Tobacco Control 2011;20(Suppl 2):ii29–ii36.21504929
Yoon M, Ryu MH, Huff RD, Belvisi MG, Smith J, Carlsten C. Effect of traffic-related air pollution on cough in adults with polymorphisms in several cough-related genes. Respiratory Research 2022;23(1):113.35509099
Younes M, Aquilina G, Castle L, Degen G, Engel KH, Fowler PJ, Frutos Fernandez MJ, Fürst P, Gundert-Remy U, Gürtler R, . Scientific opinion on flavouring group evaluation 415 (FGE.415): (E)-3-benzo[1,3]dioxol-5-yl-N,N-diphenyl-2-propenamide. EFSA Journal 2022;20(7):e07355.35814922
Yudell M, Roberts D, DeSalle R, Tishkoff S. Taking race out of human genetics engaging a century-long debate about the role of race in science. Science 2016;351(6273):564–5.26912690
Zare S, Nemati M, Zheng Y. A systematic review of consumer preference for e-cigarette attributes: flavor, nicotine strength, and type. PLoS One 2018;13(3):e0194145.29543907
Zhang M, Harrison E, Biswas L, Tran T, Liu X. Menthol facilitates dopamine-releasing effect of nicotine in rat nucleus accumbens. Pharmacology Biochemistry and Behavior 2018;175:47–52.30201386
Zhang R, Jones MM, Dornsife RE, Wu T, Sivaraman V, Tarran R, Onyenwoke RU. JUUL e-liquid exposure elicits cytoplasmic Ca2+ responses and leads to cytotoxicity in cultured airway epithelial cells. Toxicology Letters 2021;337:46–56.33253780
Zhao K, Singh S, Singh J. Effect of menthone on the in vitro percutaneous absorption of tamoxifen and skin reversibility. International Journal of Pharmaceutics 2001;219(1–2):177–81.11337177
Zhu S-H, Sun JY, Bonnevie E, Cummins SE, Gamst A, Yin L, Lee M. Four hundred and sixty brands of e-cigarettes and counting: implications for product regulation. Tobacco Control 2014;23(Suppl 3):iii3–iii9.
ZYN. Chill, n.d.; <https://us.zyn.com/all-products/>; accessed: August 4, 2022.

## Chapter 3 Appendix

### Appendix 3.1 Underlying Mechanisms and Physiology of Flavor Perceptions

#### Sense of Smell (Olfaction)

The human nose can discriminate between a wide variety of different odors. Extrapolations from psychophysical tests have determined that humans are theoretically capable of discerning 1 trillion different odors (Bushdid et al. 2014). Volatile odorant chemicals are detected by olfactory sensory nerve endings in the olfactory epithelium of the nose, either after inhalation through the nose or after retronasal olfaction following ingestion or inhalation (Figure 3A.1). The olfactory epithelium is covered in nasal mucus that dissolves odorants and, in some cases, modifies odorants through enzymatic reactions (Nagashima and Touhara 2010). Once activated, the olfactory sensory nerves signal to second-order neurons in the olfactory bulb that in turn send projections to the olfactory cortex, where odor perception is produced (Maresh et al. 2008; Murthy 2011).

Figure 3A.1 Smelling and tasting flavors in tobacco products

Notes: The olfactory epithelium contains nerve endings of olfactory neurons expressing olfactory receptors for volatile flavor chemicals inhaled through the nose or exposed through retronasal olfaction from the oral cavity or the airways when exhaling. Taste cells on the tongue, localized to taste buds and innervated by the lingual nerve, express the receptors for the basic taste qualities: sweet, bitter, umami, sour, and salty.

Illustrations are described in the notes for the figure.

The olfactory system was the first chemosensory system for which dedicated chemoreceptors were identified. In 1991, Buck and Axel became the first researchers to describe a large family of G-protein-coupled receptors (GPCRs)—the Olfactory Protein Family—whose expression was highly restricted to olfactory sensory neurons (Buck and Axel 1991). Later, Axel (2005) elaborated on this process. Olfactory receptors represent the largest receptor family in the mammalian genome. Humans express approximately 400 different olfactory receptor genes, but rodents express 1,300 genes (Touhara and Vosshall 2009; Jiang and Matsunami 2015; Keller and Vosshall 2016). Olfactory receptors couple to Golf, an olfactory-specific G-protein that activates adenylate cyclase, forming cAMP (cyclic adenosine monophosphate). This second messenger binds to a cyclic nucleotide-activated cation channel that depolarizes and allows calcium ions to flow into the cell. Calcium influx activates a chloride channel that further depolarizes and excites the olfactory sensory neurons.

Of the approximately 400 olfactory receptor genes, each olfactory sensory neuron expresses only one (Serizawa et al. 2004). Expression is monoallelic, expressing just one of the two receptor gene copies. This highly exclusive control of the expression of olfactory receptor genes has been the subject of intense research efforts (Serizawa et al. 2004).

Since odorant receptors were first identified in 1991, cognate odorants for only about 15% of the receptors have been identified (Geithe et al. 2017). Expression of odorant receptor genes in cells other than olfactory sensory neurons is technically difficult, prohibiting standard screening approaches, and many cognate odorants in the natural environment have not been identified (Krautwurst et al. 1998, 2008; Matsunami 2005; Geithe et al. 2017). However, advances in molecular biology, genetics, chemistry, and structural modeling have enabled new approaches to deorphanizing odorant receptors (Jiang and Matsunami 2015; Keller et al. 2017; Bushdid et al. 2018; Hu and Matsunami 2018; Kida et al. 2018). These studies revealed that some olfactory receptors are broadly tuned to respond to several chemically distinct odorants, and others respond only to a single known odorant chemical. A single odorant may activate several receptors with differing potency and efficacy across separate olfactory sensory neurons, a multitude of combinatorial input options are represented as distinct odors (Bushdid et al. 2014).

#### Mechanisms of Taste Perception (Gustation)

The five taste qualities (sweet, bitter, sour, salty, and umami) are sensed by taste receptor cells on the tongue (Witt and Reutter 2015). Groups of 60–100 taste receptor cells form the taste buds, which are onion-like structures with a pore on the surface that are exposed to saliva and tastants (i.e., substances eliciting taste sensations) in the oral cavity (Figure 3A.1). Taste buds are found in the papillae of the tongue, soft palate, cheeks, upper esophagus, and epiglottis. The average human has 5,000–7,500 taste buds, with a range of 2,000–10,000 (Daly et al. 2012). Contrary to an old misperception, the surface of the tongue does not contain specific regions that are dedicated to sensing single taste qualities (Feeney and Hayes 2014).

Taste receptor cells have an average life span of 10 days, after which they are replaced by new taste cells (Beidler and Smallman 1965; Conger and Wells 1969; Farbman 1980; Mistretta and Hill 2003). Some studies suggest that some taste receptor cells can last more than 3 weeks (Cho et al. 1998; Hamamichi et al. 2006). Each cell is specialized to sense only a single taste quality. When activated, the taste cells release ATP (adenosine triphosphate), a neurotransmitter that excites and activates purinergic P2X2 and P2X3 receptors on the ends of the underlying gustatory nerves (Finger et al. 2005; Kinnamon and Finger 2013). The taste buds of the tongue are innervated by nerve fibers originating in the chorda tympani and by the glossopharyngeal nerve. The palate is innervated by cranial nerve VII, and taste information from the epiglottis and larynx is relayed by cranial nerve X, also known as the vagus nerve (Erman et al. 2009). Taste information is then transmitted to the gustatory division of the nucleus tractus solitarius (NTS) in the brain. NTS neurons project into the thalamic region, further connecting with the primary (orbitofrontal) and secondary gustatory (insular-opercular) cortices (Scott and Verhagen 2000).

#### Sweet and Umami Taste Receptors

As its name indicates, sweet taste signals the presence of sugars in food, beverages, and tobacco products. Physiological studies in the 1990s revealed that both sweet and bitter taste transduction rely on G-protein signaling in taste cells, suggesting that taste receptors might be GPCRs. Two particular G-proteins, alpha subunit of transducin and gustducin, were identified in taste cells that were found to be essential for sweet and bitter taste transduction (Wong et al. 1996). A differential cloning strategy identified two novel GPCRs with expression restricted to taste cells, suggesting that these receptors might be taste receptors (Hoon et al. 1999). Genetic studies in mouse strains with large differences in the perception of sweet taste provided more insights into the role of these receptors. The polymorphic genetic locus responsible for these differences contained a gene encoding for a third GPCR with significant homology to the initial receptors (Max et al. 2001; Montmayeur et al. 2001). Together, this family of receptors was named T1R or TAS1R, with three members. The third receptor, TAS1R3, when co-expressed with the second receptor, TAS1R2, produces functional sweet-sensitive responses to sugars, such as sucrose, fructose, and many artificial sweeteners (Nelson et al. 2001; Li et al. 2002; Zhao et al. 2003). Surprisingly, when the first member of the gene family TAS1R1 was co-expressed with TAS1R3, the resulting receptor did not respond to sugars but instead to the amino acid glutamate, revealing that this combination constitutes the receptor for umami taste (Li et al. 2002; Nelson et al. 2002; Zhao et al. 2003). The TAS1R2/R3 sweet receptor proteins are found exclusively in sweet taste receptor cells, but the TAS1R1/R3 combination is found only in umami taste receptor cells, supporting the idea that taste receptor cells are specialized for only one of the five basic taste qualities (Zhang et al. 2003; Zhao et al. 2003).

#### Bitter Taste Receptors

Bitter perception is thought to have developed as a mechanism to avoid toxic chemicals in food, especially from certain toxic plants (Wooding 2006). Plant toxins—such as strychnine and ricin—are extremely bitter, and evolutionary mechanisms may have selected for traits that detect such toxins and signal intense bitter perception to produce avoidance behavior.

Individual differences in bitter perception of certain chemicals were first reported in a study by Fox (1932), in which phenylthiocarbamide (PTC) was perceived as extremely bitter by some test participants but not by others. This difference was subsequently identified as a heritable Mendelian trait, suggesting that genetic variations determine differences in taste perception (Snyder 1931; Wooding 2006). PTC non-taster status was found to be a recessive trait. The PTC-taster–non-taster duality was found to extend to other primate species, such as the chimpanzee. Subsequent studies investigated correlations between PTC-taster status and aversion to bitter chemicals occurring naturally in foods and in certain food categories. Similar genetic associations were found for PROP, another bitter tastant used in experimental studies. Gene loci associated with the polymorphisms determining sensitivity to PTC or PROP have been mapped to human chromosomes 7 and 5, respectively (Reed et al. 1999; Kim et al. 2003). Earlier, studies in mice revealed genetic determinants of sensitivity to certain bitter tastants (Capeless et al. 1992).

In 2000, a new gene family of GPCRs was identified with expression localized to taste cells of the tongue and palate (Adler et al. 2000; Chandrashekar et al. 2000; Matsunami et al. 2000). These receptors were localized in the same taste cells expressing gustducin, a taste-specific G-protein that is essential for bitter taste perception (Wong et al. 1996). Some of the genes encoding for these receptors mapped close to the PTC/PROP genetic loci in humans and to a gene locus in mice that determines bitter sensitivity (Capeless et al. 1992; Reed et al. 1999; Kim et al. 2003). This gene family was named T2R or TAS2R, and functional studies revealed that some TAS2R receptors responded to bitter tastants when expressed in heterologous cells (Chandrashekar et al. 2000; Bufe et al. 2002; Kuhn et al. 2004). Genetic studies of mice confirmed the essential roles of TAS2R receptors in bitter perception in vivo by specifically ablating sensitivity to selected bitter chemicals and by converting bitter aversion into a preference by expressing a TAS2R receptor in sweet taste cells (Mueller et al. 2005).

The human genome encodes for 25 TAS2R bitter receptor genes and additional pseudogenes (Behrens and Meyerhof 2009). In contrast, rodent genomes encode for 37 TAS2R bitter receptor genes (Behrens and Meyerhof 2009). Similar to the case with other sensory receptor genes, bitter receptor genes appear to have diverged rapidly over time, as their numbers, sequences, and pseudogenes vary widely among species (Behrens and Meyerhof 2009). The small number of receptors is dwarfed by the thousands of known bitter chemicals, suggesting that bitter receptors are broadly tuned to detect multiple bitter agents. Although bitter chemical activators for more than half the number of human bitter receptors have been found, natural bitter ligands often remain elusive (Behrens and Meyerhof 2009). Based on the discovery of TAS2 bitter receptors, the flavor industry is developing bitter blockers to inhibit certain TAS2 receptors to, in effect, increase the palatability of pharmaceutical formulations and food products.

Further confirmation for the role of TAS2 receptors in bitter sensing comes from human genetic studies that have narrowed down the polymorphic genetic region responsible for variations in the bitter perception of PTC. The gene associated with PTC taster–non-taster status has been mapped to human chromosome 7 (Reed et al. 1999; Kim et al. 2003). Positional cloning revealed that the gene encodes for TAS2R38, a member of the TAS2 bitter taste receptor gene family (Kim et al. 2003; Wooding et al. 2006). The key single nucleotide polymorphisms (SNPs) associated with the taster and non-taster haplotypes are RS713598, RS1726866, and RS10246939—all of which are located in the protein-coding region of the TAS2R38 gene. The variations in protein sequence resulting from these SNPs are PRO49ALA, ALA262Val, and VAL296ILE (PAV [taster] to AVI [non-taster]). The TAS2R38 haplotypes comprised of these SNPs (PAV and AVI) differentiate tasters of PTC bitterness (PAV/PAV and PAV/AVI genotypes) from non-tasters (AVI/AVI homozygotes).

#### Sour Taste Receptors

Sour taste, elicited by ingesting acidic foods, is an aversive taste quality thought to serve as a warning signal for spoiled foods. Similar to the other taste qualities, sourness is transduced by specialized taste receptor cells in the taste buds of the tongue. These cells express two specialized ion channels, PKD1L3 and PKD2L1. Both ion channels open in response to acidic stimuli and excite the taste cells (Huang et al. 2006; Ishimaru et al. 2006; Chang et al. 2010). PKD1L3 and PKD2L1 channels respond to acid solutions between pH 2.5 or 2.6, including H2SO4, phosphoric acid, succinic acid, tartaric acid, citric acid, hydrochloric acid, and malic acid (Inada et al. 2008). In imaging experiments for Ca^2+^, HEK 293T cells transfected with PKD1L3 and PKD2L1 responded to sour tastant, like citric acid and hydrochloric acid, and malic-like somatosensation may also play a significant role in acid detection, since low pH may cause pain sensation (Ishimaru and Matsunami 2009).

In 2018, OTOP1 was identified as a sour taste receptor (Tu et al. 2018) and confirmed in other studies (Teng et al. 2019; Zhang et al. 2019). The OTOP1 ion channel is activated by lowering pH (Teng et al. 2019). Other receptors may be involved in sour taste and in the interaction of sour with sweet taste.

Of note, PKD1L3 and PKD2L1 are transient receptor potential (TRP) ion channels and belong to the corresponding TRP family of ion channel genes (Huang et al. 2006; Ishimaru et al. 2006). TRP ion channels are present in all sensory systems and play essential roles in sensing and signal transduction (Liedtke and Heller 2007; Wu et al. 2010). TRP is a gene family with more than 30 members in mammals (Ramsey et al. 2006; Wu et al. 2010). TRP ion channels were initially identified in the photo-receptor cells of the fruit fly (Drosophila melanogaster), where these ion channels contribute to light signaling downstream of photopigment (rhodopsin) activation by light (Montell and Rubin 1989; Wes et al. 1995). As an example of the essential roles TRP ion channels play in sensing and signal transduction in mammals, mice deficient in TRPC2 are incapable of detecting pheromones and fail to discriminate between male and female cagemates (Stowers et al. 2002; Zufall 2005). TRPM5 is expressed in taste cells in the taste buds of the tongue and palate, where it is involved in the signal transduction mechanism downstream of the primary taste receptors (Perez et al. 2002, 2003; Liu and Liman 2003).

#### Salty Taste Receptors

Salty taste can stimulate appetite but also cause aversion. Similar to sweet, umami, and sour taste, appetitive salt taste is transduced by a specialized population of taste cells in the taste buds of the tongue (Chandrashekar et al. 2010). The transducer for salt taste is an ion channel, the epithelial sodium channel EnaC, which is expressed in the salt taste cells (Chandrashekar et al. 2010). In contrast to the sweet and bitter receptors, EnaC is expressed in many organs of the human body, including the kidneys. EnaC is the target of amiloride, a diuretic that is known to reduce salt taste (Heck et al. 1984; Brand et al. 1985). EnaC conducts sodium ions from salt that flow into the cell, which excites and releases neurotransmitters to activate the underlying gustatory nerve (Heck et al. 1984; Brand et al. 1985; Eylam and Spector 2003). High concentrations of salt generate both astringent and aversive sensations (Chandrashekar et al. 2010; Oka et al. 2013). Experiments in mice have shown that high concentrations of salt create an aversive effect by activating both bitter and sour taste pathways (Oka et al. 2013). Coolants—such as Frescolat ML [(-)-Menthyl lactate] that are used in oral care, food, and cosmetics (PubChem 2004)—can increase saltiness of a product at different levels (Table 3.4).

#### Somatosensory Perception of Flavor Chemicals: Hot, Warm, Cold, Texture, Pain, and Irritation

In addition to the olfactory and gustatory systems, many flavorants elicit sensations by activating nerves of the somatosensory system. These nerves transduce physical stimuli, such as temperature (hot, cold); mechanical stimuli (pressure, stroking, texture); pain; and irritation. The oral cavity and nasal passages are innervated by one type of cranial nerve, namely, trigeminal sensory nerves in the head (Figure 3A.2). Inhaling heated smoke activates C-fibers, a subset of trigeminal nerves that mediates warmth perception, heat-induced pain, and the sensation of itching and coarseness. Activation of trigeminal nerves by irritants in the nose triggers the sneezing reflex and nasal secretions. These nerves are activated by pungent spices, such as black pepper, mustard, and wasabi. Trigeminal nerves also contain a nerve subpopulation activated by cooling, such as by drinking cold water or eating ice cream. This nerve population is sensitive to menthol and other cooling agents. The back of the throat, larynx, trachea, bronchi, and lungs are innervated by sensory neurons of a different cranial nerve, namely, the vagus nerve, which originates in the nodose and jugular ganglia. When activated by an irritant stimulus, these neurons can trigger the cough reflex and the perception of burning, bronchoconstriction, and secretions (Figure 3A.3).

Figure 3A.2 Sensing tobacco chemicals and physical stimuli by trigeminal nerve endings

Notes: The sensory nerves innervating the head structures, including the oral cavity and nasal passages, originate in the trigeminal ganglion. These nerves sense irritants in smoke; irritant flavors; menthol and other cooling agents; physical stimuli (e.g., heat, cooling); and mechanical stimuli that contribute to perceptions of viscosity and texture.

Illustrations are described in the notes for the figure.

##### Transient Receptor Potential Ion Channels as Sensors for Chemical and Thermal Stimuli

Since the late 1990s, molecular cloning efforts have led to the discovery of unique receptors for chemical and physical stimuli in sensory nerves. One class of receptors consists of members of the TRP ion channel family that respond to both chemical and thermal stimuli (hot, cold). (As noted previously, TRP ion channels are present in, and appear to play a role in, all sensory systems.) These receptors play important roles in sensing the chemesthetic (burning, cooling) properties of flavorant chemicals added to tobacco products, irritants produced during tobacco curing or combustion, and thermal (heat) stimuli associated with tobacco smoke inhalation.

Figure 3A.3 Responses by airway nerves to stimuli from chemicals in tobacco products

Notes: The chemosensory nerves innervating the larynx, trachea, bronchi, and lung originate in the vagal sensory ganglia (nodose, jugular). When excited, these neurons trigger the cough reflex and the perception of burning, and they trigger glandular secretions. When stimulated, these neurons release neuropeptides that promote and maintain inflammation during infections and in chronic conditions, such as asthma.

Illustrations are described in the notes for the figure.

###### TRPM8: The Cold and Menthol Receptor

The sensation of cooling is initiated when cold-sensitive sensory nerve fibers are excited by cooling or a cooling chemesthetic agent. Hensel and Zotterman (1951) first described cold-sensitive nerve fibers, demonstrating that these fibers are also sensitive to menthol, the cooling chemesthetic natural product of peppermint. In 2002, researchers identified TRP melastatin 8 (TRPM8), a cold- and menthol-sensitive receptor in trigeminal sensory neurons (Figure 3A.4) (McKemy et al. 2002; Peier et al. 2002; Jordt et al. 2003; McKemy 2018). TRPM8 is also activated by numerous other cooling compounds that are used as additives, including AG-3-5 (also called icilin), Coolact P, Cooling Agent 10, FrescolatMGA, FrescolatML, Geraniol, Hydroxycitronellal, Linalool, PMD38, WS-3, and WS-23 (Table 3.4) (Chuang et al. 2004; McKemy 2007). L-menthol stimulates TRPM8 severalfold more than other menthol stereoisomers do (Behrendt et al. 2004; Bandell et al. 2006).

Mice deficient in TRPM8 have deficits in cold sensing and in the excitability of their cold-induced neurons (Bautista et al. 2007; Colburn et al. 2007; Dhaka et al. 2007). Such mice fail to discriminate between warm and cool temperatures in the range of 15°–25°C. Expression profiling of TRPM8 transcripts revealed that TRPM8 is strongly expressed in the trigeminal neurons that innervate the oral cavity and nose (Figure 3A.2) (McKemy et al. 2002; Peier et al. 2002).

The analgesic effects of menthol and other cooling agents, such as icilin and WS-12, occur when TRPM8 is activated in peripheral sensory nerves and, subsequently, central inhibitory circuits that suppress sensory input from nociceptors are activated (Galeotti et al. 2002; Proudfoot et al. 2006; Liu et al. 2013). A mechanism mediated by TRPM8 and initiated by exposure to vapor from menthol inhibits respiratory irritation responses in mice to several irritants in tobacco smoke (Willis et al. 2011). Intriguingly, menthol has not only analgesic effects but also suppresses itching (Kardon et al. 2014; Stander et al. 2017; Liu and Jordt 2018; Palkar et al. 2018). Similar to the case with pain and respiratory irritation, TRPM8 in cold-sensitive nerve fibers is essential for menthol to act as an antipruritic (i.e., anti-itch) treatment (Liu and Jordt 2018; Palkar et al. 2018). TRPM8-expressing fibers have been shown to connect to inhibitory circuits in the spinal cord that dampen input from nociceptors when menthol or a cool stimulus is applied (Liu and Jordt 2018; Palkar et al. 2018).

Figure 3A.4 Structure of TRPM8, the menthol and cold receptor

Notes: A. Top-down view of the central ion pore (left) and side view (right) of the tetrameric ion channel (Yin et al. 2018). B. Transmembrane structural segment of TRPM8 shows the putative menthol binding site (green) coordinated by amino acid residues in transmembrane domain 4 and adjacent domains. Side view (left) and top-down view (right) of the TRPA1 ion channel, a major irritant receptor in peripheral sensory neurons, resolved by cryo-electron microscopy. TRPA1 has a tetrameric structure with a central ion-conducting pore, allowing sodium and calcium ions to flow into sensory nerve endings when the channel is activated by an irritant. Regulatory sites, including irritant binding sites, are localized to the large cytosolic domain of the protein (Yin et al. 2018). C. Activation of TRPM8 ion channel by cold temperature. Increase in currents conducted by a TRPM8 expressing cell (top) upon perfusion with gradually cooling physiological buffer (McKemy et al. 2002). A large inward current (top) developed when the bath temperature was reduced and reversed when the bath temperature was increased again. TRPA1 = transient receptor potential ankyrin 1; TRPM8 = transient receptor potential melastatin 8.

Illustrations are described in the notes for the figure.

###### TRPA1: The Receptor of Reactive Irritants from Smoke

The lungs are highly sensitive to reactive airborne chemicals, which can damage the delicate respiratory epithelia and alveolar structures that are essential for gas exchange (Bein and Leikauf 2011; Conklin et al. 2017). Tobacco smoke, smoke from fires, and smog contain high concentrations of airborne electrophilic volatile chemicals known to cause lung disease. Acrolein, an unsaturated aldehyde, is produced by the combustion of organic matter and is the major electrophile in tobacco smoke; concentrations of acrolein in mainstream cigarette smoke can exceed 50 parts per million (Brunnemann et al. 1990). Acrolein is on FDA’s list of HPHCs in tobacco products (FDA 2012). Acrolein has strong irritant effects, causing stinging and burning sensations in the eyes, nose, mouth, and throat (Achanta and Jordt 2017). These sensations originate in the somatosensory nerve endings in the cornea of the eye, nose, mouth, throat, and trachea. Acrolein triggers sneezing and cough, both of which are defensive reflexes designed to clear the airway of potentially injurious irritants, to preserve respiratory function, and to initiate evasive and avoidance behavior (Alarie 1973; Willis et al. 2011). Acrolein stimulates vagal lung-innervating sensory nerves, causing reflex apnea and triggering inflammatory responses through the release of neuropeptides (Lee et al. 1992; Turner et al. 1993).

TRP ankyrin1 (TRPA1) was identified in 2006 as a receptor for acrolein in sensory neurons (Figure 3A.5) (Bautista et al. 2006; Bessac and Jordt 2008). TRPA1 was initially discovered in nociceptors, which are pain-transducing sensory neurons, as a sensor for painfully cold temperatures and a target for mustard oil (allyl isothiocyanate), the pungent ingredient in mustard, horseradish, and wasabi (Jordt et al. 2004). Similar to acrolein, mustard oil is a small reactive chemical (an isothiocyanate) that reacts with proteins to form a chemical bond. For decades, neuroscientists used mustard oil and similar natural pain-inducing products to study pain mechanisms and to develop new analgesic treatments (Jordt et al. 2004; Bautista et al. 2005). When mustard oil binds to TRPA1, the channel opens and allows sodium and calcium ions to permeate the nerve endings, triggering an action potential that propagates along the nerve fiber toward the spinal cord.

Nerve connections in the spinal cord integrate the pain signal and transduce it to the brain, where pain is represented in the somatosensory cortex (Basbaum et al. 2009). The discovery of TRP ion channels in pain-sensing nerves was a breakthrough in the neuroscience of pain, initiating many follow-up studies that investigated the roles of ion channels in chemical sensing and acute and chronic pain conditions.

Subsequent studies identified many other electrophilic and oxidizing activators of TRPA1, including croton aldehyde and methacrolein, which are also found in tobacco smoke and ozone and chlorine gas, and are all strongly noxious irritants (Bessac et al. 2008; Escalera et al. 2008; Taylor-Clark and Undem 2010). Structure–function analysis revealed that TRPA1 is not a receptor in the classical sense; instead, it is a sensor for chemical reactivity that is activated by electrophiles and oxidants through covalent modification (Hinman et al. 2006; Macpherson et al. 2007). A cluster of cysteine residues in the cytosolic N-terminus of TRPA1 is essential for activation by electrophiles; C621, a highly reactive cysteine residue, is the likely reactive center (Hinman et al. 2006; Macpherson et al. 2007; Bahia et al. 2016) (Figure 3A.6).

Figure 3A.5 Structure of TRPA1, the major irritant in smoke and aldehyde receptor

Notes: Side view (left) and top-down view (right) of the TRPA1 ion channel, the major irritant receptor in peripheral sensory neurons, resolved by cryo-electron microscopy (Suo et al. 2020). TRPA1 has a tetrameric structure with a central ionconducting pore, allowing sodium and calcium ions to flow into sensory nerve endings when the channel is activated by an irritant. Regulatory sites, including irritant binding sites, are localized to the large cytosolic domain of the protein. TRPA1 is activated by noxious natural products, such as mustard oil (allyl isothiocyanate), the pungent ingredient in mustard. It is the primary target of the major irritants in smoke, acrolein and croton aldehyde, and formaldehyde. Aldehyde flavor chemicals in tobacco products, such as cinnamaldehyde, activate TRPA1 and may cause irritation. TRPA1 = transient receptor potential ankyrin 1.

Illustrations and structural formulas are described in the notes for the figure.

Many of the flavor chemicals added to tobacco products are aldehydes. These aldehydes usually have a pleasant smell, but when concentrations exceed certain levels, flavor aldehydes can be irritating, eliciting burning sensations in the eyes and airways (Bandell et al. 2004). One example is cinnamaldehyde, the flavor aldehyde in cinnamon flavors. Cinnamaldehyde is an alpha-beta-unsaturated aldehyde and has chemical reactivity similar to the irritating smoke aldehydes: acrolein and croton aldehyde (Figure 3A.6). Cinnamaldehyde has been identified as a TRPA1 agonist, causing both pain and respiratory irritation (Bandell et al. 2004). Benzaldehyde, vanillin, and acetaldehyde—listed on FDA’s list of HPHCs in tobacco products (FDA 2012)—and other fragrant and flavor aldehydes have been shown to activate TRPA1 (Bang et al. 2007; Mihara and Shibamoto 2015; Erythropel et al. 2017). TRPA1 is also activated by reaction products of flavor aldehydes and propylene glycol, the e-cigarette solvent. For example, benzaldehyde propylene glycol acetal, formed from benzaldehyde and propylene glycol in chemically unstable e-liquids, is a more efficacious TRPA1 agonist than benzaldehyde, suggesting these chemicals act as irritants (Erythropel et al. 2019).

Figure 3A.6 Mechanism of irritant activation of TRPA1

Notes: TRPA1 is activated by irritants in smoke and other irritating airborne chemicals that covalently react with the receptor on electrophile binding sites that are clustered within the cytosolic N-terminus of the channel protein. Cysteine 621 (inset) is a key site highly sensitive to electrophile modification (Paulsen et al. 2015). The Michael addition reaction of cysteine with the major smoke irritant, acrolein, is shown. TRPA1 = transient receptor potential ankyrin 1.

Illustration is described in the notes for the figure.

L-menthol has been identified as a TRPA1 agonist, suggesting that TRPA1 may mediate its irritant effects (Bandell et al. 2004; Macpherson et al. 2006; Xiao et al. 2008). The binding site for menthol has been mapped to the fifth transmembrane domain of the TRPA1 peptide (Xiao et al. 2008). Higher concentrations of L-menthol are required to activate TRPA1 than those that are required to activate TRPM8, and significant differences in sensitivity have been reported across species (Macpherson et al. 2006; Karashima et al. 2007; Xiao et al. 2008).

Methyl salicylate, the wintergreen flavor, is also an agonist of TRPA1, as is eugenol, which is found in clove and is also a flavor chemical (Bandell et al. 2004; Inoue et al. 2012; Chung et al. 2014). Both methyl salicylate and eugenol are used as topical analgesics and counter-irritants at high concentrations, likely acting through receptor desensitization.

###### TRPV1: The Heat or Acid Receptor

TRP vanilloid 1 (TRPV1) was the first sensory neuron-specific TRP ion channel discovered, identified through its interaction with capsaicin, the pungent ingredient in chili peppers (Caterina et al. 1997). TRPV1 is also activated by noxious heat, mediating heat pain, and by acidity that potentiates its sensitivity to thermal and chemical stimuli (Tominaga et al. 1998; Jordt et al. 2000). Similar to TRPA1, TRPV1 is activated by methyl salicylate, the wintergreen flavor, and by eugenol, the clove flavor (Ohta et al. 2009). TRPV1 was identified as a target of flavorant-solvent reaction products—including vanillinpropylene glycol acetal (Erythropel et al. 2019)—that are vaporized from chemically unstable e-liquids, likely contributing to their irritant effects. TRPV1 is sensitized by nicotine, increasing sensitivity to chemical agonists (Liu et al. 2004).

### References

Achanta S, Jordt SE. TRPA1: Acrolein meets its target. Toxicology and Applied Pharmacology 2017;324:45–50.28284857
Adler E, Hoon MA, Mueller KL, Chandrashekar J, Ryba NJ, Zuker CS. A novel family of mammalian taste receptors. Cell 2000;100(6):693–702.10761934
Alarie Y. Sensory irritation by airborne chemicals. CRC Critical Reviews in Toxicology 1973;2(3):299–363.4131690
Axel R. Scents and sensibility: a molecular logic of olfactory perception (Nobel lecture). Angewandte Chemie 2005;44(38):6110–27.16175526
Bahia PK, Parks TA, Stanford KR, Mitchell DA, Varma S, Stevens SM Jr, Taylor-Clark TE. The exceptionally high reactivity of Cys 621 is critical for electrophilic activation of the sensory nerve ion channel TRPA1. Journal of General Physiology 2016;147(6):451–65.27241698
Bandell M, Dubin AE, Petrus MJ, Orth A, Mathur J, Hwang SW, Patapoutian A. High-throughput random mutagenesis screen reveals TRPM8 residues specifically required for activation by menthol. Nature Neuroscience 2006;9(4):493–500.16520735
Bandell M, Story GM, Hwang SW, Viswanath V, Eid SR, Petrus MJ, Earley TJ, Patapoutian A. Noxious cold ion channel TRPA1 is activated by pungent compounds and bradykinin. Neuron 2004;41(6):849–57.15046718
Bang S, Kim KY, Yoo S, Kim YG, Hwang SW. Transient receptor potential A1 mediates acetaldehyde-evoked pain sensation. European Journal of Neuroscience 2007;26(9):2516–23.17970723
Basbaum AI, Bautista DM, Scherrer G, Julius D. Cellular and molecular mechanisms of pain. Cell 2009;139(2):267–84.19837031
Bautista DM, Jordt SE, Nikai T, Tsuruda PR, Read AJ, Poblete J, Yamoah EN, Basbaum AI, Julius D. TRPA1 mediates the inflammatory actions of environmental irritants and proalgesic agents. Cell 2006;124(6):1269–82.16564016
Bautista DM, Movahed P, Hinman A, Axelsson HE, Sterner O, Hogestatt ED, Julius D, Jordt SE, Zygmunt PM. Pungent products from garlic activate the sensory ion channel TRPA1. Proceedings of the National Academy of Sciences of the United States of America 2005;102(34):12248–52.16103371
Bautista DM, Siemens J, Glazer JM, Tsuruda PR, Basbaum AI, Stucky CL, Jordt SE, Julius D. The menthol receptor TRPM8 is the principal detector of environmental cold. Nature 2007;448(7150):204–8.17538622
Behrendt HJ, Germann T, Gillen C, Hatt H, Jostock R. Characterization of the mouse cold-menthol receptor TRPM8 and vanilloid receptor type-1 VR1 using a fluorometric imaging plate reader (FLIPR) assay. British Journal of Pharmacology 2004;141(4):737–45.14757700
Behrens M, Meyerhof W. Mammalian bitter taste perception. Results and Problems in Cell Differentiation 2009;47:203–20.19145413
Beidler LM, Smallman RL. Renewal of cells within taste buds. Journal of Cell Biology 1965;27(2):263–72.5884625
Bein K, Leikauf GD. Acrolein—a pulmonary hazard. Molecular Nutrition & Food Research 2011;55(9):1342–60.21994168
Bessac BF, Jordt SE. Breathtaking TRP channels: TRPA1 and TRPV1 in airway chemosensation and reflex control. Physiology (Bethesda, Md.) 2008;23:360–70.19074743
Bessac BF, Sivula M, von Hehn CA, Escalera J, Cohn L, Jordt SE. TRPA1 is a major oxidant sensor in murine airway sensory neurons. Journal of Clinical Investigation 2008;118(5):1899–910.18398506
Brand JG, Teeter JH, Silver WL. Inhibition by amiloride of chorda tympani responses evoked by monovalent salts. Brain Research 1985;334(2):207–14.3995317
Brunnemann KD, Kagan MR, Cox JE, Hoffmann D. Analysis of 1,3-butadiene and other selected gas-phase components in cigarette mainstream and sidestream smoke by gas chromatography-mass selective detection. Carcinogenesis 1990;11(10):1863–8.2208599
Buck L, Axel R. A novel multigene family may encode odorant receptors: a molecular basis for odor recognition. Cell 1991;65(1):175–87.1840504
Bufe B, Hofmann T, Krautwurst D, Raguse JD, Meyerhof W. The human TAS2R16 receptor mediates bitter taste in response to beta-glucopyranosides. Nature Genetics 2002;32(3):397–401.12379855
Bushdid C, de March CA, Matsunami H, Golebiowski J. Numerical models and in vitro assays to study odorant receptors. Methods in Molecular Biology 2018;1820:77–93.29884939
Bushdid C, Magnasco MO, Vosshall LB, Keller A. Humans can discriminate more than 1 trillion olfactory stimuli. Science 2014;343(6177):1370–2.24653035
Capeless CG, Whitney G, Azen EA. Chromosome mapping of Soa, a gene influencing gustatory sensitivity to sucrose octaacetate in mice. Behavior Genetics 1992;22(6):655–63.1290451
Caterina MJ, Schumacher MA, Tominaga M, Rosen TA, Levine JD, Julius D. The capsaicin receptor: a heat-activated ion channel in the pain pathway. Nature 1997;389(6653):816–24.9349813
Chandrashekar J, Kuhn C, Oka Y, Yarmolinsky DA, Hummler E, Ryba NJ, Zuker CS. The cells and peripheral representation of sodium taste in mice. Nature 2010;464(7286):297–301.20107438
Chandrashekar J, Mueller KL, Hoon MA, Adler E, Feng L, Guo W, Zuker CS, Ryba NJ. T2Rs function as bitter taste receptors. Cell 2000;100(6):703–11.10761935
Chang RB, Waters H, Liman ER. A proton current drives action potentials in genetically identified sour taste cells. Proceedings of the National Academy of Sciences of the United States of America 2010;107(51):22320–5.21098668
Cho YK, Farbman AI, Smith DV. The timing of alpha-gustducin expression during cell renewal in rat vallate taste buds. Chemical Senses 1998;23(6):735–42.9915120
Chuang HH, Neuhausser WM, Julius D. The super-cooling agent icilin reveals a mechanism of coincidence detection by a temperature-sensitive TRP channel. Neuron 2004;43(6):859–69.15363396
Chung G, Im ST, Kim YH, Jung SJ, Rhyu MR, Oh SB. Activation of transient receptor potential ankyrin 1 by eugenol. Neuroscience 2014;261:153–60.24384226
Colburn RW, Lubin ML, Stone DJ Jr, Wang Y, Lawrence D, D’Andrea MR, Brandt MR, Liu Y, Flores CM, Qin N. Attenuated cold sensitivity in TRPM8 null mice. Neuron 2007;54(3):379–86.17481392
Conger AD, Wells MA. Radiation and aging effect on taste structure and function. Radiation Research 1969;37(1):31–49.5762923
Conklin DJ, Malovichko MV, Zeller I, Das TP, Krivokhizhina TV, Lynch BH, Lorkiewicz P, Agarwal A, Wickramasinghe N, Haberzettl P, . Biomarkers of chronic acrolein inhalation exposure in mice: implications for tobacco product-induced toxicity. Toxicological Sciences 2017;158(2):263–74.28482051
Daly BP, Daly MP, Minniti N, Daly JM. Sense of taste (effect on behavior). In: Ramachandran VS, editor. Encyclopedia of Human Behavior. 2nd ed. Cambridge (MA): Academic Press, 2012:373–8.
Dhaka A, Murray AN, Mathur J, Earley TJ, Petrus MJ, Patapoutian A. TRPM8 is required for cold sensation in mice. Neuron 2007;54(3):371–8.17481391
Erman AB, Kejner AE, Hogikyan ND, Feldman EL. Disorders of cranial nerves IX and X. Seminars in Neurology 2009;29(1):85–92.19214937
Erythropel HC, Jabba SV, DeWinter TM, Falinski M, Anastas PT, Zimmerman JB, Jordt SE. Chemical adducts of flavorants with e-cigarette liquid solvents act as modulators of respiratory irritant receptors. American Journal of Respiratory and Critical Care Medicine 2017;195:A7583.
Erythropel HC, Jabba SV, DeWinter TM, Mendizabal M, Anastas PT, Jordt SE, Zimmerman JB. Formation of flavorant-propylene glycol adducts with novel toxicological properties in chemically unstable e-cigarette liquids. Nicotine & Tobacco Research 2019;21(9):1248–58.30335174
Escalera J, von Hehn CA, Bessac BF, Sivula M, Jordt SE. TRPA1 mediates the noxious effects of natural sesquiterpene deterrents. Journal of Biological Chemistry 2008;283(35):24136–44.18550530
Eylam S, Spector AC. Oral amiloride treatment decreases taste sensitivity to sodium salts in C57BL/6J and DBA/2J mice. Chemical Senses 2003;28(5):447–58.12826540
Farbman AI. Renewal of taste bud cells in rat circumvallate papillae. Cell and Tissue Kinetics 1980;13(4):349–57.7428010
Feeney EL, Hayes JE. Regional differences in suprathreshold intensity for bitter and umami stimuli. Chemosensory Perception 2014;7(3–4):147–57.25485034
Finger TE, Danilova V, Barrows J, Bartel DL, Vigers AJ, Stone L, Hellekant G, Kinnamon SC. ATP signaling is crucial for communication from taste buds to gustatory nerves. Science 2005;310(5753):1495–9.16322458
Fox AL. The relationship between chemical constitution and taste. Proceedings of the National Academy of Sciences of the United States of America 1932;18(1):115–20.16577421
Galeotti N, Di Cesare Mannelli L, Mazzanti G, Bartolini A, Ghelardini C. Menthol: a natural analgesic compound. Neuroscience Letters 2002;322(3):145–8.11897159
Geithe C, Protze J, Kreuchwig F, Krause G, Krautwurst D. Structural determinants of a conserved enantiomer-selective carvone binding pocket in the human odorant receptor OR1A1. Cellular and Molecular Life Sciences 2017;74(22):4209–29.28656349
Hamamichi R, Asano-Miyoshi M, Emori Y. Taste bud contains both short-lived and long-lived cell populations. Neuroscience 2006;141(4):2129–38.16843606
Heck GL, Mierson S, DeSimone JA. Salt taste transduction occurs through an amiloride-sensitive sodium transport pathway. Science 1984;223(4634):403–5.6691151
Hensel H, Zotterman Y. The effect of menthol on the thermoreceptors. Acta Physiologica Scandinavica 1951;24(1):27–34.14877581
Hinman A, Chuang HH, Bautista DM, Julius D. TRP channel activation by reversible covalent modification. Proceedings of the National Academy of Sciences of the United States of America 2006;103(51):19564–8.17164327
Hoon MA, Adler E, Lindemeier J, Battey JF, Ryba NJ, Zuker CS. Putative mammalian taste receptors: a class of taste-specific GPCRs with distinct topographic selectivity. Cell 1999;96(4):541–51.10052456
Hu XS, Matsunami H. High-throughput odorant receptor deorphanization via phospho-S6 ribosomal protein immunoprecipitation and mRNA profiling. Methods in Molecular Biology 2018;1820:95–112.29884940
Huang AL, Chen X, Hoon MA, Chandrashekar J, Guo W, Trankner D, Ryba NJ, Zuker CS. The cells and logic for mammalian sour taste detection. Nature 2006;442(7105):934–8.16929298
Inada H, Kawabata F, Ishimaru Y, Fushiki T, Matsunami H, Tominaga M. Off-response property of an acid-activated cation channel complex PKD1L3–PKD2L1. EMBO Reports 2008;9(7):690–7.18535624
Inoue M, Fujita T, Goto M, Kumamoto E. Presynaptic enhancement by eugenol of spontaneous excitatory transmission in rat spinal substantia gelatinosa neurons is mediated by transient receptor potential A1 channels. Neuroscience 2012;210:403–15.22426238
Ishimaru Y, Inada H, Kubota M, Zhuang H, Tominaga M, Matsunami H. Transient receptor potential family members PKD1L3 and PKD2L1 form a candidate sour taste receptor. Proceedings of the National Academy of Sciences of the United States of America 2006;103(33):12569–74.16891422
Ishimaru Y, Matsunami H. Transient receptor potential (TRP) channels and taste sensation. Journal of Dental Research 2009;88(3):212–8.19329452
Jiang Y, Matsunami H. Mammalian odorant receptors: functional evolution and variation. Current Opinion in Neurobiology 2015;34:54–60.25660959
Jordt SE, Bautista DM, Chuang HH, McKemy DD, Zygmunt PM, Hogestatt ED, Meng ID, Julius D. Mustard oils and cannabinoids excite sensory nerve fibres through the TRP channel ANKTM1. Nature 2004;427(6971):260–5.14712238
Jordt SE, McKemy DD, Julius D. Lessons from peppers and peppermint: the molecular logic of thermosensation. Current Opinion in Neurobiology 2003;13(4):487–92.12965298
Jordt SE, Tominaga M, Julius D. Acid potentiation of the capsaicin receptor determined by a key extracellular site. Proceedings of the National Academy of Sciences of the United States of America 2000;97(14):8134–9.10859346
Karashima Y, Damann N, Prenen J, Talavera K, Segal A, Voets T, Nilius B. Bimodal action of menthol on the transient receptor potential channel TRPA1. Journal of Neuroscience 2007;27(37):9874–84.17855602
Kardon AP, Polgar E, Hachisuka J, Snyder LM, Cameron D, Savage S, Cai X, Karnup S, Fan CR, Hemenway GM, . Dynorphin acts as a neuromodulator to inhibit itch in the dorsal horn of the spinal cord. Neuron 2014;82(3):573–86.24726382
Keller A, Gerkin RC, Guan Y, Dhurandhar A, Turu G, Szalai B, Mainland JD, Ihara Y, Yu CW, Wolfinger R, . Predicting human olfactory perception from chemical features of odor molecules. Science 2017;355(6327):820–6.28219971
Keller A, Vosshall LB. Olfactory perception of chemically diverse molecules. BMC Neuroscience 2016;17(1):55.27502425
Kida H, Fukutani Y, Mainland JD, de March CA, Vihani A, Li YR, Chi Q, Toyama A, Liu L, Kameda M, . Vapor detection and discrimination with a panel of odorant receptors. Nature Communications 2018;9(1):4556.
Kim UK, Jorgenson E, Coon H, Leppert M, Risch N, Drayna D. Positional cloning of the human quantitative trait locus underlying taste sensitivity to phenylthiocarbamide. Science 2003;299(5610):1221–5.12595690
Kinnamon SC, Finger TE. A taste for ATP: neurotransmission in taste buds. Frontiers in Cellular Neuroscience 2013;7:264.24385952
Krautwurst D. Human olfactory receptor families and their odorants. Chemistry & Biodiversity 2008;5(6):842–52.18618407
Krautwurst D, Yau KW, Reed RR. Identification of ligands for olfactory receptors by functional expression of a receptor library. Cell 1998;95(7):917–26.9875846
Kuhn C, Bufe B, Winnig M, Hofmann T, Frank O, Behrens M, Lewtschenko T, Slack JP, Ward CD, Meyerhof W. Bitter taste receptors for saccharin and acesulfame K. Journal of Neuroscience 2004;24(45):10260–5.15537898
Lee BP, Morton RF, Lee LY. Acute effects of acrolein on breathing: role of vagal bronchopulmonary afferents. Journal of Applied Physiology 1992;72(3):1050–6.1568959
Li X, Staszewski L, Xu H, Durick K, Zoller M, Adler E. Human receptors for sweet and umami taste. Proceedings of the National Academy of Sciences of the United States of America 2002;99(7):4692–6.11917125
Liedtke WB, Heller S. TRP Ion Channel Function in Sensory Transduction and Cellular Signaling Cascades. Boca Raton (FL): CDC Press/Taylor & Francis, 2007.
Liu B, Fan L, Balakrishna S, Sui A, Morris JB, Jordt SE. TRPM8 is the principal mediator of menthol-induced analgesia of acute and inflammatory pain. Pain 2013;154(10):2169–77.23820004
Liu B, Jordt SE. Cooling the itch via TRPM8. Journal of Investigative Dermatology 2018;138(6):1254–6.29793621
Liu D, Liman ER. Intracellular Ca2+ and the phospholipid PIP2 regulate the taste transduction ion channel TRPM5. Proceedings of the National Academy of Sciences of the United States of America 2003;100(25):15160–5.14657398
Liu L, Zhu W, Zhang ZS, Yang T, Grant A, Oxford G, Simon SA. Nicotine inhibits voltage-dependent sodium channels and sensitizes vanilloid receptors. Journal of Neurophysiology 2004;91(4):1482–91.14657192
Macpherson LJ, Dubin AE, Evans MJ, Marr F, Schultz PG, Cravatt BF, Patapoutian A. Noxious compounds activate TRPA1 ion channels through covalent modification of cysteines. Nature 2007;445(7127):541–5.17237762
Macpherson LJ, Hwang SW, Miyamoto T, Dubin AE, Patapoutian A, Story GM. More than cool: promiscuous relationships of menthol and other sensory compounds. Molecular and Cellular Neurosciences 2006;32(4):335–43.16829128
Maresh A, Rodriguez Gil D, Whitman MC, Greer CA. Principles of glomerular organization in the human olfactory bulb—implications for odor processing. PLoS One 2008;3(7):e2640.18612420
Matsunami H. Functional expression of mammalian odorant receptors. Chemical Senses 2005;30(Suppl 1): i95–i96.15738214
Matsunami H, Montmayeur JP, Buck LB. A family of candidate taste receptors in human and mouse. Nature 2000;404(6778):601–4.10766242
Max M, Shanker YG, Huang L, Rong M, Liu Z, Campagne F, Weinstein H, Damak S, Margolskee RF. Tas1r3, encoding a new candidate taste receptor, is allelic to the sweet responsiveness locus Sac. Nature Genetics 2001;28(1):58–63.11326277
McKemy DD. Molecular basis of peripheral innocuous cold sensitivity. Handbook of Clinical Neurology 2018;156:57–67.30454609
McKemy DD. TRPM8: The cold and menthol receptor. In: Liedtke WB, Heller S, editors. TRP Ion Channel Function in Sensory Transduction and Cellular Signaling Cascades. Boca Raton (FL): CRC Press/Taylor & Francis, 2007.
McKemy DD, Neuhausser WM, Julius D. Identification of a cold receptor reveals a general role for TRP channels in thermosensation. Nature 2002;416(6876):52–8.11882888
Mihara S, Shibamoto T. The role of flavor and fragrance chemicals in TRPA1 (transient receptor potential cation channel, member A1) activity associated with allergies. Allergy, Asthma, and Clinical Immunology 2015;11(1):11.
Mistretta CM, Hill DL. Development of the taste system: basic neurobiology. In: Doty RL, editor. Handbook of Olfaction and Gustation. New York (NY): Marcel Dekker, 2003:759–82.
Montell C, Rubin GM. Molecular characterization of the drosophila TRP locus: a putative integral membrane protein required for phototransduction. Neuron 1989;2(4):1313–23.2516726
Montmayeur JP, Liberles SD, Matsunami H, Buck LB. A candidate taste receptor gene near a sweet taste locus. Nature Neuroscience 2001;4(5):492–8.11319557
Mueller KL, Hoon MA, Erlenbach I, Chandrashekar J, Zuker CS, Ryba NJ. The receptors and coding logic for bitter taste. Nature 2005;434(7030):225–9.15759003
Murthy VN. Olfactory maps in the brain. Annual Review of Neuroscience 2011;34:233–58.
Nagashima A, Touhara K. Enzymatic conversion of odorants in nasal mucus affects olfactory glomerular activation patterns and odor perception. Journal of Neuroscience 2010;30(48):16391–8.21123585
Nelson G, Chandrashekar J, Hoon MA, Feng L, Zhao G, Ryba NJ, Zuker CS. An amino-acid taste receptor. Nature 2002;416(6877):199–202.11894099
Nelson G, Hoon MA, Chandrashekar J, Zhang Y, Ryba NJ, Zuker CS. Mammalian sweet taste receptors. Cell 2001;106(3):381–90.11509186
Ohta T, Imagawa T, Ito S. Involvement of transient receptor potential vanilloid subtype 1 in analgesic action of methylsalicylate. Molecular Pharmacology 2009;75(2):307–17.18987162
Oka Y, Butnaru M, von Buchholtz L, Ryba NJ, Zuker CS. High salt recruits aversive taste pathways. Nature 2013;494(7438):472–5.23407495
Palkar R, Ongun S, Catich E, Li N, Borad N, Sarkisian A, McKemy DD. Cooling relief of acute and chronic itch requires TRPM8 channels and neurons. Journal of Investigative Dermatology 2018;138(6):1391–9.29288650
Paulsen CE, Armache JP, Gao Y, Cheng Y, Julius D. Structure of the TRPA1 ion channel suggests regulatory mechanisms. Nature 2015;520(7548):511–7.25855297
Peier AM, Moqrich A, Hergarden AC, Reeve AJ, Andersson DA, Story GM, Earley TJ, Dragoni I, McIntyre P, Bevan S, . A TRP channel that senses cold stimuli and menthol. Cell 2002;108(5):705–15.11893340
Perez CA, Huang L, Rong M, Kozak JA, Preuss AK, Zhang H, Max M, Margolskee RF. A transient receptor potential channel expressed in taste receptor cells. Nature Neuroscience 2002;5(11):1169–76.12368808
Perez CA, Margolskee RF, Kinnamon SC, Ogura T. Making sense with TRP channels: store-operated calcium entry and the ion channel Trpm5 in taste receptor cells. Cell Calcium 2003;33(5–6):541–9.12765699
Proudfoot CJ, Garry EM, Cottrell DF, Rosie R, Anderson H, Robertson DC, Fleetwood-Walker SM, Mitchell R. Analgesia mediated by the TRPM8 cold receptor in chronic neuropathic pain. Current Biology 2006;16(16):1591–605.16920620
PubChem. Menthyl lactate, 2004; <https://pubchem.ncbi.nlm.nih.gov/compound/62151#section=Household-Products>; accessed: June 6, 2022.
Ramsey IS, Delling M, Clapham DE. An introduction to TRP channels. Annual Review of Physiology 2006;68:619–47.
Reed DR, Nanthakumar E, North M, Bell C, Bartoshuk LM, Price RA. Localization of a gene for bitter-taste perception to human chromosome 5p15. American Journal of Human Genetics 1999;64(5):1478–80.10205283
Scott TR, Verhagen JV. Taste as a factor in the management of nutrition. Nutrition 2000;16(10):874–85.11054592
Serizawa S, Miyamichi K, Sakano H. One neuron-one receptor rule in the mouse olfactory system. Trends in Genetics 2004;20(12):648–53.15522461
Snyder LH. Inherited Taste Deficiency. Science 1931;74(1910):151–2.17782493
Stander S, Augustin M, Roggenkamp D, Blome C, Heitkemper T, Worthmann AC, Neufang G. Novel TRPM8 agonist cooling compound against chronic itch: results from a randomized, double-blind, controlled, pilot study in dry skin. Journal of the European Academy of Dermatology and Venereology 2017;31(6):1064–8.27862339
Stowers L, Holy TE, Meister M, Dulac C, Koentges G. Loss of sex discrimination and male-male aggression in mice deficient for TRP2. Science 2002;295(5559):1493–500.11823606
Suo Y, Wang Z, Zubcevic L, Hsu AL, He Q, Borgnia MJ, Ji RR, Lee SY. Structural insights into electrophile irritant sensing by the human TRPA1 channel. Neuron 2020;105(5):882–894.e5.31866091
Taylor-Clark TE, Undem BJ. Ozone activates airway nerves via the selective stimulation of TRPA1 ion channels. Journal of Physiology 2010;588(Pt 3):423–33.20008466
Teng B, Wilson CE, Tu YH, Joshi NR, Kinnamon SC, Liman ER. Cellular and neural responses to sour stimuli require the proton channel Otop1. Current Biology 2019;29(21):3647–56.e5.31543453
Tominaga M, Caterina MJ, Malmberg AB, Rosen TA, Gilbert H, Skinner K, Raumann BE, Basbaum AI, Julius D. The cloned capsaicin receptor integrates multiple pain-producing stimuli. Neuron 1998;21(3):531–43.9768840
Touhara K, Vosshall LB. Sensing odorants and pheromones with chemosensory receptors. Annual Review of Physiology 2009;71:307–32.
Tu YH, Cooper AJ, Teng B, Chang RB, Artiga DJ, Turner HN, Mulhall EM, Ye W, Smith AD, Liman ER. An evolutionarily conserved gene family encodes protonselective ion channels. Science 2018;359(6379):1047–50.29371428
Turner CR, Stow RB, Talerico SD, Christian EP, Williams JC. Protective role for neuropeptides in acute pulmonary response to acrolein in guinea pigs. Journal of Applied Physiology 1993;75(6):2456–65.7510277
U.S. Food and Drug Administration. Harmful and potentially harmful constituents in tobacco products and tobacco smoke: established list, April 2012; <https://www.fda.gov/tobacco-products/rules-regulations-and-guidance/harmful-and-potentially-harmful-constituents-tobacco-products-and-tobacco-smoke-established-list>; accessed: July 5, 2023.
Wes PD, Chevesich J, Jeromin A, Rosenberg C, Stetten G, Montell C. TRPC1, a human homolog of a Drosophila store-operated channel. Proceedings of the National Academy of Sciences of the United States of America 1995;92(21):9652–6.7568191
Willis DN, Liu B, Ha MA, Jordt SE, Morris JB. Menthol attenuates respiratory irritation responses to multiple cigarette smoke irritants. FASEB Journal 2011; 25(12):4434–44.21903934
Witt M, Reutter K. Anatomy of the tongue and taste buds. In: Doty RL, editor. Handbook of Olfaction and Gustation. Third ed. Hoboken (NJ): Wiley Blackwell, 2015:637–64.
Wong GT, Gannon KS, Margolskee RF. Transduction of bitter and sweet taste by gustducin. Nature 1996;381(6585):796–800.8657284
Wooding S. Phenylthiocarbamide: a 75-year adventure in genetics and natural selection. Genetics 2006;172(4):2015–23.16636110
Wooding S, Bufe B, Grassi C, Howard MT, Stone AC, Vazquez M, Dunn DM, Meyerhof W, Weiss RB, Bamshad MJ. Independent evolution of bitter-taste sensitivity in humans and chimpanzees. Nature 2006;440(7086):930–4.16612383
Wu LJ, Sweet TB, Clapham DE. International Union of Basic and Clinical Pharmacology. LXXVI. Current progress in the mammalian TRP ion channel family. Pharmacological Reviews 2010;62(3):381–404.20716668
Xiao B, Dubin AE, Bursulaya B, Viswanath V, Jegla TJ, Patapoutian A. Identification of transmembrane domain 5 as a critical molecular determinant of menthol sensitivity in mammalian TRPA1 channels. Journal of Neuroscience 2008;28(39):9640–51.18815250
Yin Y, Wu M, Zubcevic L, Borschel WF, Lander GC, Lee SY. Structure of the cold- and menthol-sensing ion channel TRPM8. Science 2018;359(6372):237–41.29217583
Zhang J, Jin H, Zhang W, Ding C, O’Keeffe S, Ye M, Zuker CS. Sour sensing from the tongue to the brain. Cell 2019;179(2):392–402.e15.31543264
Zhang Y, Hoon MA, Chandrashekar J, Mueller KL, Cook B, Wu D, Zuker CS, Ryba NJ. Coding of sweet, bitter, and umami tastes: different receptor cells sharing similar signaling pathways. Cell 2003;112(3):293–301.12581520
Zhao GQ, Zhang Y, Hoon MA, Chandrashekar J, Erlenbach I, Ryba NJ, Zuker CS. The receptors for mammalian sweet and umami taste. Cell 2003;115(3):255–66.14636554
Zufall F. The TRPC2 ion channel and pheromone sensing in the accessory olfactory system. Naunyn-Schmiedebergs Archives of Pharmacology 2005;371(4):245–50.15871013

1 The definition of tobacco product was later amended in the Consolidated Appropriations Act of 2022, to include products that contain nicotine from any source (Consolidated Appropriations Act 2022). As of August 2023, FDA’s deeming authority as it applies to premium cigars is the subject of litigation after the District Court of the District of Columbia vacated a portion of the deeming rule related to this product (Cigar Association of America v. FDA 2023).

2 Sales reflect nominal dollars not adjusted for inflation.

3 Ibid.

4 Jabba and colleagues (2022) further note that “[T]he absorption efficiency for chemicals by the respiratory system is higher than the efficiency of the digestive tract and usually, an oral-to-inhalation ratio of 2 is applied for route-to-route [R2R] extrapolation [citing The Interdepartmental Group on Health Risks from Chemicals 2006; European Chemicals Agency 2012], reflecting the higher absorption of toxicants following inhalation [citing The Interdepartmental Group on Health Risks from Chemicals 2006; European Chemicals Agency 2012; Schröder et al. 2016]. In this study, R2R extrapolation was not used, however, if applied, the MOE values would be even lower, reflecting an even higher risk associated with inhalation of these two synthetic cooling agents at various daily consumption volumes.”

* URL was active on the access date shown in the reference entry but was no longer active when this Surgeon General’s report was released.