# Chapter 2 Disparities in Tobacco Use and Exposure to Secondhand Tobacco Smoke

## Introduction

Despite the considerable progress made in reducing the toll of tobacco-related disease since the release of the 1964 Surgeon General’s report, tobacco-related health disparities and disparities in the patterns of tobacco use persist in the United States. Disparities in tobacco use have multifaceted influences that go beyond individual and intrapersonal factors, including the tobacco industry’s aggressive marketing and promotion of flavored and fragranced products, such as mentholated products. Chapters 1, 3, 4, and 5 of the current report describe these and other factors that have influenced tobacco-related health disparities.

Health disparities may be understood as differences in health outcomes between two populations, between a specific population and the general population, or as former Surgeon General Dr. David Satcher stated in 1999, between a minority and a majority population—although it is not always clear how to define these populations (Satcher 1999; Harper and Lynch 2005).

In 2021, Centers for Disease Control and Prevention (CDC) published Identifying and Eliminating tobacco-related Health Disparities: Key Outcome Indicators for Evaluating Comprehensive Tobacco Control Programs (CDC 2022). This guide presents an overview of concepts and considerations when measuring tobacco-related disparities. In addition to identifying a reference group and choosing to use absolute scales based on differences or relative scales based on ratios, other important considerations include accounting for differences in group sizes, using differential weighting, using pairwise or summary approaches to compare differences across groups, and more. The choice of disparity measure (absolute or relative), the choice of a specific reference group, and the magnitude or statistical significance of the difference may lead to conflicting conclusions about whether a disparity exists. Thus, measuring disparities on both absolute and relative scales may provide a more complete understanding of disparities and the magnitude of differences between populations (CDC 2022).

Various conceptual, ethical, and methodological issues should be considered when deciding how to measure and communicate tobacco-related health disparities (Harper and Lynch 2005). Throughout this chapter, disparities in patterns of tobacco use are discussed in multiple ways. Differences in outcomes between populations are highlighted where 95% confidence intervals (CIs) do not overlap.

This chapter presents patterns and trends in commercial tobacco use and exposure to secondhand tobacco smoke among the groups of people that are more affected by tobacco use than others, including people from populations defined by racial and ethnic identity, sexual orientation, and gender identity; people of lower socioeconomic status (SES); people with mental health conditions or substance use disorders; members of certain occupational groups; and people who reside in rural or other selected geographic settings. In this chapter, data are presented on youth and adults, including information on different adult populations by age. Analyses focus on the persistence of specific patterns of tobacco product use, such as frequency of use or polytobacco use, among certain populations and differences in exposure among them to secondhand tobacco smoke. The analyses have also been informed by the theory of intersectionality, as introduced in Chapter 1, which holds that being in two or more groups that may have a higher risk for health disparities may worsen disparities in tobacco use, exposure to secondhand tobacco smoke, and tobacco-related health outcomes (Cole 2009).

Patterns of tobacco product use focus on cigarettes, other combustible products (such as cigars and little cigars), noncombustible products (such as smokeless tobacco), and electronic cigarette (e-cigarette) products that deliver nicotine. Having comprehensive information about these products and the key patterns and trends in their use, with a focus on disparities, is critical to the development and maintenance of health promotion programs to reduce tobacco-related illness and death. tobacco product use. Appendix 2.1 and Table 2.1 describe the seven principal national surveys that inform this chapter. Although other national surveys exist that assess behaviors related to tobacco product use, these seven surveys were selected to serve as primary data sources based on the strength of their methodologies, salience of content, recency of data, and completeness with which they cover populations of interest. Appendix 2.2 describes the various measures of tobacco product use reported in this chapter.

## Methods

In the United States, a variety of national surveillance systems collect tobacco-specific data for youth and adults. These systems conduct surveys that typically assess behaviors related to cigarette smoking and, sometimes, the use of other tobacco products; some surveys also collect information about important aspects of tobacco use, such as quit attempts. The surveys use different methods and provide comparable, but not identical, measures of tobacco product use. Appendix 2.1 and Table 2.1 describe the seven principal national surveys that inform this chapter. Although other national surveys exist that assess behaviors related to tobacco product use, these seven surveys were selected to serve as primary data sources based on the strength of their methodologies, salience of content, recency of data, and completeness with which they cover populations of interest. Appendix 2.2 describes the various measures of tobacco product use reported in this chapter.

The data from these principal national surveys may be limited based on the measures they include and the populations they sample to estimate tobacco product use across multiple populations. For example, various factors may influence the content of the surveys. Some of the surveys cover a broad range of public health topics with only limited tobacco-specific content. Additionally, the Office of Management and Budget requires accounting for respondent burden in determining survey content. Proposing new questions often calls for the deletion of existing survey items. Furthermore, some surveys require voting by states before including any newly proposed questions in the final survey instrument. In the past, few national surveillance systems met certain practice recommendations for measuring sexual orientation and gender identity, including assessing transgender-inclusive gender identity (Patterson et al. 2017). While most of the national surveillance systems used in this chapter ask questions about sexual orientation, fewer ask questions about gender identity. Moreover, when collected, data are often presented in aggregate, which may mask important differences between groups (National Academies of Sciences, Engineering, and Medicine 2022; National Science and Technology Council 2023). Results from these systems are also limited to the languages in which the surveys are offered and may not capture small or hard-to-reach populations that are examined in state- or community-level assessments (Friis et al. 2006; Tong et al. 2010; Mukherjea et al. 2018). Methodologic limitations are further discussed in Appendix 2.1.

Cross-sectional data presented in this chapter are from the following seven national surveillance systems: the Youth Risk Behavior Surveillance System (YRBSS), the National Youth Tobacco Survey (NYTS), the National Survey on Drug Use and Health (NSDUH), the National Health Interview Survey (NHIS), the Tobacco Use Supplement to the Current Population Survey (TUS-CPS), the Behavioral Risk Factor Surveillance System (BRFSS), and the National Health and Nutrition Examination Survey (NHANES). Each of these population-based surveys gather anonymous or confidentially obtained self-reported data. Generally, self-reported data are accurate enough for tracking general patterns of tobacco use in populations (Brener et al. 2003; U.S. Department of Health and Human Services [USDHHS] 2004).

The YRBSS conducts both state and local surveys as well as a national survey. Its national Youth Risk Behavior Survey (YRBS) uses probability samples of public and private high school students in Grades 9–12 who anonymously fill out questionnaires that are administered in schools. The findings from this survey are representative of the U.S. high school population. National YRBS data from 1991 to 2019 are used in this report to illustrate trends over time.

The NYTS provides national data on long-term, intermediate, and short-term indicators key to the design, implementation, and evaluation of comprehensive tobacco prevention and control programs. The NYTS uses probability samples of public and private middle school students (Grades 6–8) and high school students (Grades 9–12) who anonymously fill out questionnaires that are administered in schools. The findings of the NYTS are representative of the U.S. middle school and high school population. The NYTS also serves as a baseline for comparing progress toward meeting selected Healthy People 2030 goals for reducing tobacco use among youth (CDC n.d.i). Items measured as part of the NYTS survey include ever and past-30-day use of a range of tobacco products and correlates of tobacco use such as demographics, minors’ access to tobacco, and exposure to secondhand tobacco smoke. This chapter presents data from the 2011–2021 NYTS.

The NSDUH is conducted under the direction of the federal Substance Abuse and Mental Health Services Administration (SAMHSA). Using household-based sampling, the NSDUH is designed to represent the entire civilian, noninstitutionalized population 12 years of age and older in the United States. A major strength of the NSDUH is that its national sample is allocated strategically across age-specific populations. Starting in 2014 and continuing through 2019, the allocation of the NSDUH sample was 25% for adolescents (12–17 years of age), 25% for young adults (18–25 years of age), and 50% for adults (26 years of age and older). The sample of adults was further divided into three subgroups: 26–34 years of age (15%), 35–49 years of age (20%), and 50 years of age and older (15%) (SAMHSA 2019). The NSDUH includes youth who have dropped out of school or who are frequently absent and who are more likely to smoke than youth who stay in school or are not frequently absent (Tice et al. 2017). The NSDUH is the only national survey that has a wide range of tobacco use measures that can be compared across the three priority populations (youth, young adults, and all adults). Unless otherwise indicated, past-month use refers to use on 1 or more days during the past 30 days. In-person questionnaires for the NSDUH are completed confidentially in the home with audio computer-assisted self-interviewing so that only the respondent is aware of the questions being asked. Unless otherwise indicated, all NSDUH data presented in this chapter are from the 2019 survey.

Table 2.1 Sources of national survey data on tobacco use used for this report, United States

Characteristic | BRFSS | NHIS | TUS-CPS | YRBS | NYTS | NSDUH | NHANES
Sponsoring agency or organization | CDC, HRSA, AoA, VA, and SAMHSA | CDC | NCI (2018–2019 wave co-sponsored by FDA) | CDC | CDC and FDA since 2011 | SAMHSA | CDC
Type of survey | Cross-sectional | Cross-sectional | Cross-sectional and longitudinal | Cross-sectional | Cross-sectional | Cross-sectional | Cross-sectional
Years | 2020 | - 2019–2021; - Cancer Control Supplements 1992–1993, 2005, 2010, 2011–2013, and 2015–2018; - Some longitudinal analyses dating back to 1964^a^ | - 2018–2019; - Reference years: 2001–2002, 2003, 2006–2007, 2010–2011, and 2014–2015 | 1991–2019 | 2020, 2021 | 2019 | 1988–2018
Mode of survey administration | Telephone-based questionnaire that state health departments conduct monthly over landline and cellular telephones using a standardized questionnaire and technical and methodologic assistance provided by CDC | Computer-assisted, personal interview | Questionnaire via telephone and in-person interviews | School-based, self-administered, paper-based questionnaire | School-based, self-administered questionnaire | Audio, computer-assisted, self-interview | Home interview and health examination in a mobile examination center
Response rate | - 2020: 34.5–67.2%; - The median survey response rate for all states, territories, and Washington, DC, in 2020 was 47.9% | - 2019:; – Sample adults: 59.1%; - 2020:; – Sample adults: 48.9%; - 2021:; – Sample adults: 50.9% | - 2018–2019: Average self-response rate (for all waves combined) 57.6% | - 2019:; – School: 75.1%; – Student: 80.3%; - Overall: 60.3% | - 2020:; – School: 49.9%; – Student: 87.4%; – Overall: 43.6%; - 2021:; – School: 54.9%; - Student: 81.2%; - Overall: 44.6% | - 2019 weighted screening response rate:; – 70.5% (original data); - 2019 weighted interview response rate for computer-assisted interview:; – 64.9% (original data) | - 2017–2018:; – Interviewed sample: 51.9%; - Examined sample: 48.8%
Sample size | - 2020: 401,958 adults ≥18 years of age | - Adults ≥18 years of age:; – 2019: 31,997; – 2020: 31,568; – 2021: 29,482 | - 2018–2019: 137,471 | - 2019: 13,677 students in grades 9–12 | - 2020: 14,531 students in grades 6–12; - 2021: 20,413 students in grades 6–12 | - 2019 restricted-use dataset: 67,625; - Public use dataset: 56,136 | - 2017–2018:; – Interviewed sample: 9,254; – Examined sample: 8,704
Type of tobacco use examined | Cigarettes, smokeless tobacco, and e-cigarettes | Cigarettes, cigars, pipes, smokeless tobacco, and e-cigarettes | Cigarettes, cigars, smokeless tobacco, and e-cigarettes | Cigarettes, cigars, smokeless tobacco, and electronic vapor products (i.e., e-cigarettes) | Cigarettes, smokeless tobacco, snus, cigars, e-cigarettes, hookah, pipes, dissolvable tobacco products, heated tobacco products, nicotine pouches, and bidis | Cigarettes, cigars, pipes, and smokeless (snuff, dip, and chewing tobacco or snus) | Self-reported tobacco use and serum cotinine levels

Notes:AoA = Administration on Aging; BRFSS = Behavioral Risk Factor Surveillance System; CDC = Centers for Disease Control and Prevention; FDA = U.S. Food and Drug Administration; HRSA = Health Resources and Services Administration; N/A = not applicable; NCHS = National Center for Health Statistics; NCI = National Cancer Institute; NHANES = National Health and Nutrition Examination Survey; NHIS = National Health Interview Survey; NSDUH = National Survey on Drug Use and Health; SAMHSA = Substance Abuse and Mental Health Services Administration; TUS-CPS = Tobacco Use Supplement—Current Population Survey; VA = U.S. Department of Veterans Affairs; YRBS = Youth Risk Behavior Survey.

a The content and structure of the NHIS questionnaire and interview were redesigned in 2019. One adult is randomly selected from each household for the sample. Updates were made to the weighting process for the 2019 sample of adults, limiting comparisons with previous years.

The NHIS is an annual cross-sectional household interview survey of civilian, noninstitutionalized adults 18 years of age and older. The NHIS has been a primary source of health data on the adult population in the United States since 1957. NHIS data on tobacco product use, which are available from 1965 to 2021, are used in this report to illustrate trends over time. In 2019, the content and structure of the NHIS were updated. Estimates of tobacco product use before and after 2019 may not be directly comparable; thus, figures portraying these data include a break in the trend line in 2019. In addition, data from the 2019–2021 NHIS were pooled when available into a combined dataset and analyzed to obtain estimates of patterns of tobacco product use.

The TUS-CPS is a nationally representative survey that has been sponsored by the National Cancer Institute (NCI) since 1992. The TUS-CPS is a key source of data, including data on health disparities, at the national and state levels and, to some degree, at the local level. The survey collects data from civilian, noninstitutionalized adults 18 years of age and older. The most recent data related to cigarette smoking, other tobacco product use, and cessation attempts were collected in July 2018, January 2019, and May 2019.

The BRFSS collects data on U.S. adults 18 years of age and older regarding risk behaviors and preventive health practices that can affect their health status. The BRFSS is conducted using random-digit dialing techniques on both landlines and mobile phones. The survey collects data from all 50 states, the District of Columbia, Puerto Rico, the U.S. Virgin Islands, Guam, American Samoa, and Palau. The BRFSS data presented in this chapter are from the 2019 survey.

The NHANES is a cross-sectional survey designed to assess the health and nutritional status of the civilian, noninstitutionalized population in the United States. The NHANES includes a home interview; health examinations at a mobile examination center where biologic specimens are collected; and laboratory specimen testing, including serum cotinine (a metabolite of nicotine that is widely used as a biomarker of nicotine exposure), for participants 3 years of age and older. Data from this survey are used to estimate the prevalence of major diseases, health conditions, environmental exposures, and risk factors for diseases. The NHANES data presented in this chapter are from 1988 to 2018 and explore the prevalence of exposure to secondhand tobacco smoke among the populations discussed in this report.

This chapter presents weighted prevalence estimates and 95% CIs. Because of the focus on patterns of tobacco use across populations, differences between groups are reported where CIs do not overlap, without formal statistical testing. Most data presented in this chapter are based on primary analyses conducted on these seven national surveillance systems. However, secondary analyses from the existing published literature are also included when available.

## Tobacco Use Among Racial and Ethnic Groups

Disparities in tobacco use by race and ethnicity have been present for decades (Table 2.2) and were the focus of the 1998 Surgeon General’s report (USDHHS 1998). Many of the disparities described in the 1998 report are still present today, with new disparities emerging or gaining notice.

The categorization of people by race and ethnicity has expanded since the 1998 report, which examined five groups of people: African American, American Indian and Alaska Native, Asian American and Pacific Islander, Hispanic, and White. This report analyzes seven broad racial and ethnic categories established by the Office of Management and Budget: American Indian and Alaska Native, Asian American, Black or African American, White, Hispanic or Latino, Native Hawaiian and Other Pacific Islander, and non-Hispanic multiple race (Federal Register 1997).

Throughout this chapter, all categories presented other than Hispanic or Latino are non-Hispanic. However, Hispanic or Latino people can be of any race. Although disaggregated data are needed to reflect the heterogeneity within each of these groups (e.g., “Asian American” includes Chinese, Japanese, Vietnamese, Korean, and South Asian people), the presentation of estimates for different populations is limited both by the measures used to assess racial and ethnic identity and the number of participants in each group that was sampled for inclusion in the surveys. In addition to racial and ethnic groups, this report assesses the role that immigration to the United States and assimilation in this country may play in determining the likelihood of some tobacco product use outcomes.

Table 2.2 Prevalence of adults, 18 years of age and older, who currently smoked cigarettes,^a^ overall and by race and ethnicity;^b,c^ National Health Interview Survey (NHIS) 1965–2021,^d^ United States

Year | Percent that currently smoked cigarettes (95% CI)
Year | Overall | White, non-Hispanic | Black, non-Hispanic | Hispanic | American Indian and Alaska Native | Asian American and Pacific Islander | Other
1965 | 42.4 (42.0–42.8) | 42.1 (41.6–42.5) | 45.8 (44.4–47.2) | 40.2 (32.1–48.2)^b^ | N/A | N/A | N/A
1970 | 37.4 (36.6–38.1) | 37.0 (36.3–37.8) | 41.4 (39.5–43.4) | 27.2 (23.3–31.2)^b^ | N/A | N/A | N/A
1974 | 37.1 (36.4–37.7) | 36.4 (35.7–37.1) | 44.0 (41.8–46.1) | 31.2 (25.5–36.9)^b^ | N/A | N/A | N/A
1978 | 34.1 (33.2–35.1) | 34.0 (33.0–35.0) | 37.5 (34.4–40.5) | 31.6 (27.8–35.4) | 45.2 (32.0–58.4) | 24.2 (17.1–31.3) | 27.4 (18.2–36.6)
1980 | 33.2 (32.3–34.2) | 33.0 (31.9–34.0) | 37.1 (33.9–40.2) | 29.8 (25.9–33.7) | —^e^ | 24.1 (16.7–31.6) | 29.9 (16.9–42.9)
1983 | 32.1 (31.5–32.8) | 32.3 (31.5–33.0) | 35.9 (33.7–38.0) | 25.3 (22.9–27.6) | 41.3 (30.9–51.7) | 20.5 (15.9–25.1) | 37.4 (29.3–45.4)
1985 | 30.1 (29.5–30.7) | 29.9 (29.2–30.6) | 35.0 (33.1–36.9) | 25.9 (23.6–28.2) | 33.5 (22.5–44.4) | 21.8 (17.3–26.2) | 31.0 (21.7–40.3)
1987 | 28.8 (28.2–29.3) | 29.0 (28.4–29.6) | 33.0 (31.4–34.6) | 23.6 (21.8–25.3) | 37.2 (26.9–47.4) | 14.3 (12.0–16.7) | 25.4 (18.1–32.8)
1990 | 25.5 (25.0–26.0) | 25.8 (25.3–26.4) | 26.2 (24.9–27.4) | 23.0 (21.0–25.0) | 39.0 (30.1–47.8) | 16.4 (13.3–19.4) | 19.8 (14.9–24.7)
1991 | 25.7 (25.2–26.2) | 26.2 (25.6–26.7) | 28.9 (27.4–30.4) | 20.0 (18.3–21.8) | 31.7 (24.4–38.9) | 16.0 (12.9–19.0) | 23.5 (17.0–29.9)
1992 | 26.5 (25.8–27.2) | 27.2 (26.3–28.0) | 27.8 (25.8–29.8) | 20.7 (19.0–22.4) | 39.1 (32.4–45.8) | 15.4 (12.3–18.4) | 25.2 (18.1–32.4)
1993 | 25.0 (24.3–25.6) | 25.4 (24.6–26.2) | 26.2 (24.5–27.9) | 20.4 (17.7–23.1) | 38.7 (30.2–47.3) | 18.1 (13.7–22.4) | 23.5 (15.3–31.7)
1994 | 25.5 (24.8–26.3) | 26.3 (25.5–27.2) | 27.2 (25.1–29.3) | 19.5 (17.0–22.1) | 42.0 (32.9–51.1) | 14.0 (10.6–17.3) | 22.6 (15.9–29.4)
1995 | 24.7 (24.2–25.2) | 25.5 (24.9–26.1) | 25.9 (24.9–26.8) | 18.3 (17.6–19.1) | 36.2 (27.7–44.8) | 16.6 (15.3–17.9) | 28.5 (24.1–32.8)
1997 | 24.7 (24.2–25.3) | 25.2 (24.5–25.9) | 26.8 (25.3–28.4) | 20.4 (19.1–21.6) | 32.1 (23.3–40.8) | 16.5 (13.9–19.2) | 34.0 (28.0–40.0)
1998 | 24.1 (23.5–24.7) | 24.9 (24.2–25.7) | 24.5 (22.8–26.2) | 19.1 (17.6–20.6) | 40.6 (28.4–52.9) | 13.6 (10.5–16.7) | 31.8 (25.7–37.9)
1999 | 23.5 (22.9–24.1) | 24.3 (23.5–25.0) | 24.1 (22.0–26.3) | 18.1 (16.8–19.4) | 41.2 (32.6–49.9) | 15.0 (11.8–18.2) | 30.0 (24.4–35.5)
2000 | 23.3 (22.6–23.9) | 24.1 (23.3–24.8) | 23.2 (22.0–24.5) | 18.6 (17.2–19.9) | 36.0 (26.4–45.6) | 14.6 (11.7–17.5) | 35.4 (28.7–42.1)
2001 | 22.8 (22.2–23.4) | 24.0 (23.3–24.8) | 22.3 (20.7–23.8) | 16.7 (15.3–18.0) | 32.7 (24.8–40.6) | 12.1 (9.4–14.8) | 34.3 (29.3–39.3)
2002 | 22.5 (21.9–23.1) | 23.6 (22.8–24.4) | 22.4 (20.9–24.0) | 16.7 (15.4–17.9) | 40.8 (30.9–50.6) | 13.4 (11.0–15.8) | 30.2 (24.6–35.8)
2003 | 21.6 (21.0–22.2) | 22.7 (22.0–23.4) | 21.5 (19.9–23.0) | 16.4 (15.2–17.6) | 39.7 (27.8–51.6) | 11.7 (9.2–14.3) | 30.2 (24.2–36.2)
2004 | 20.9 (20.3–21.5) | 22.2 (21.4–22.9) | 20.2 (18.5–21.9) | 15.0 (13.8–16.2) | 33.4 (25.1–41.8) | 11.3 (8.9–13.8) | 36.7 (29.7–43.6)
2005 | 20.9 (20.3–21.5) | 21.9 (21.1–22.7) | 21.5 (19.8–23.1) | 16.2 (15.1–17.4) | 32.0 (22.2–41.7) | 13.3 (10.4–16.3) | 23.9 (18.0–29.8)
2006 | 20.8 (20.1–21.5) | 21.9 (21.1–22.8) | 23.0 (21.1–24.8) | 15.2 (13.7–16.7) | 32.4 (19.6–45.2) | 10.4 (8.4–12.5) | 30.6 (24.2–37.0)
2007 | 19.8 (19.0–20.6) | 21.4 (20.4–22.4) | 19.8 (18.2–21.5) | 13.3 (11.7–14.9) | 36.4 (22.8–49.9) | 9.6 (7.9–11.2) | 25.7 (18.2–33.2)
2008 | 20.6 (19.9–21.4) | 22.0 (21.1–23.0) | 21.2 (19.4–23.1) | 15.8 (14.2–17.4) | 32.4 (23.7–41.1) | 9.8 (7.5–12.1) | 25.2 (19.1–31.4)
2009 | 20.6 (19.9–21.3) | 22.1 (21.2–23.0) | 21.3 (19.6–22.9) | 14.5 (13.2–15.9) | 23.2 (12.8–33.5) | 12.0 (10.0–14.0) | 27.7 (21.9–33.5)
2010 | 19.3 (18.8–19.9) | 21.0 (20.3–21.8) | 20.6 (19.1–22.1) | 12.5 (11.4–13.6) | 31.4 (22.3–40.5) | 9.2 (7.6–10.8) | 25.9 (20.4–31.4)
2011 | 19.0 (18.4–19.6) | 20.6 (19.8–21.4) | 19.4 (18.1–20.8) | 12.9 (11.8–14.1) | 31.5 (21.4–41.7) | 9.9 (8.4–11.4) | 25.5 (20.7–30.3)
2012 | 18.1 (17.5–18.7) | 19.7 (18.9–20.4) | 18.1 (16.7–19.4) | 12.5 (11.3–13.7) | 21.8 (15.0–28.6) | 10.7 (9.1–12.3) | 25.9 (21.2–30.5)
2013 | 17.8 (17.2–18.4) | 19.4 (18.6–20.3) | 18.3 (16.8–19.7) | 12.1 (11.0–13.2) | 26.1 (18.5–33.7) | 9.6 (7.9–11.4) | 27.7 (22.8–32.6)
2014 | 16.8 (16.1–17.4) | 18.2 (17.3–19.1) | 17.5 (16.1–18.8) | 11.2 (10.2–12.2) | 29.2 (19.6–38.8) | 9.5 (7.7–11.2) | 26.8 (20.9–32.7)
2015 | 15.1 (14.5–15.7) | 16.6 (15.8–17.3) | 16.7 (15.2–18.2) | 10.1 (9.1–11.0) | 21.9 (16.6–27.1) | 7.0 (5.6–8.5) | 18.7 (14.9–22.5)
2016 | 15.5 (14.8–16.1) | 16.6 (15.9–17.4) | 16.5 (14.7–18.3) | 10.7 (9.2–12.3) | 31.8 (24.1–39.5) | 9.0 (7.1–10.9) | 23.8 (19.4–28.3)
2017 | 14.0 (13.4–14.6) | 15.2 (14.4–15.9) | 14.9 (13.1–16.6) | 9.9 (8.6–11.1) | 24.0 (14.4–33.6) | 7.1 (5.5–8.8) | 19.5 (15.1–23.8)
2018 | 13.7 (13.1–14.3) | 15.0 (14.3–15.7) | 14.6 (12.8–16.3) | 9.8 (8.4–11.2) | 22.6 (12.0–33.3) | 7.1 (5.2–8.9) | 19.1 (14.7–23.5)
2019 | 14.0 (13.4–14.5) | 15.5 (14.9–16.2) | 14.9 (13.3–16.4) | 8.8 (7.8–9.9) | 20.9 (9.8–31.9) | 7.2 (5.4–9.0) | 19.7 (15.7–23.8)
2020 | 12.5 (11.9–13.0) | 13.3 (12.7–14.0) | 14.4 (12.6–16.3) | 8.0 (7.0–9.2) | 27.1 (17.4–38.6) | 8.0 (6.4–9.9) | 19.5 (14.9–24.7)
2021 | 11.5 (11.1–12.0) | 12.9 (12.3–13.6) | 11.7 (10.4–13.2) | 7.7 (6.8–8.7) | —^e^ | 5.4 (4.2–6.9) | 14.9 (11.6–19.0)

Source: NHIS, National Center for Health Statistics, public use data, 2021.

Notes: CI = confidence interval; N/A = not available.

a For NHIS survey years 1965–1991, people who currently smoked included adults who reported having smoked more than 100 cigarettes in their lifetimes and specified that they currently smoked. Since 1992, people who currently smoked included adults who reported having smoked at least 100 cigarettes in their lifetimes and specified that they currently smoked “every day” or “some days.”

b All other categories, not necessarily Hispanic (NHIS did not code for Hispanic as a separate demographic from 1965 to 1974).

c Beginning with the 1999 NHIS, “Asian American and Pacific Islander” was assessed separately as “Asian” and “Native Hawaiian and Other Pacific Islander.” For purposes of trends, these categories are combined here.

d The NHIS underwent a redesign in 2019. Because of the changes in weighting and design methodology, direct comparisons between estimates beginning in 2019 and earlier years should be made with caution because the effects of these changes have not been fully evaluated yet.

e Unstable estimate is not presented because of a relative standard error >0.3 or number of unweighted denominators <50.

### Patterns of Ever and Current Use of Cigarettes

#### Youth

Table 2.3 presents YRBS data from 2019 on the prevalence of cigarette use among high school students by race and ethnicity. Ever use of cigarettes was lowest among Asian students (8.9%; 95% CI: 6.7–11.8), followed by Black students (14.2%; 95% CI, 10.7–18.7), Native Hawaiian and Other Pacific Islander students (23.7%; 95% CI, 13.4–38.4), White students (25.6%; 95% CI, 22.2–29.4), Hispanic students (26.1%; 95% CI, 21.0–32.0), non-Hispanic multiple race students (30.6%; 95% CI, 25.9–35.6), and American Indian and Alaska Native students (37.9%; 95% CI, 25.0–52.8).

Past-30-day (current) use was highest among American Indian and Alaska Native students (20.6%; 95% CI, 10.8–35.9), followed by non-Hispanic multiple race students (8.0%; 95% CI, 5.5–11.3), White students (6.7%; 95% CI, 5.3–8.4), Hispanic students (6.0%; 95% CI, 4.3–8.4), Native Hawaiian and Other Pacific Islander students (4.5%; 95% CI, 1.2–15.2), Black students (3.3%; 95% CI, 2.3–4.6), and Asian students (2.3%; 95% CI, 1.2–4.3).

Among youth (12–17 years of age), the incidence of the onset of cigarette smoking, defined as having moved from never smoking to daily smoking during the year, was highest among White youth. According to an analysis of NSDUH data from 2006 to 2013, the annual rate of smoking onset from multivariate regression models was significantly higher among White youth (boys: 0.026; girls: 0.026) compared with Black (boys: 0.009; girls: 0.009), Hispanic (boys: 0.015; girls: 0.012), and Asian/Pacific Islander (boys: 0.011; girls: 0.009) youth (Thompson et al. 2018). However, during this period, the rate of decline in the onset of cigarette smoking was faster for White youth than for youth in other racial and ethnic groups (Thompson et al. 2018). For example, White boys experienced a 0.2 percentage point decline in smoking onset for each successive annual cohort during 2006–2013, while the annual decline in smoking onset was 0.1 percentage points each year among Black boys. Among White girls, there was a 0.3 percentage point decline in smoking onset per year, while both Black and Hispanic girls experienced a decline in smoking onset of 0.1 percentage points per year (Thompson et al. 2018).

#### Adults

Among young adults (18–25 years of age), trends in the incidence of the onset of cigarette smoking were similar to that observed among youth (12–17 years of age). Specifically, declines in the onset of cigarette smoking (becoming a new smoker) were slower among Black and Hispanic young women than White young women. In addition, the onset of smoking increased among successive cohorts of Black and Hispanic young men compared with White and Asian young men (Thompson et al. 2018). Despite faster declines in the rate of smoking onset among White young adults compared with other racial and ethnic groups, the overall rate of smoking onset was higher during 2006–2013 among White young adults than it was among all other racial and ethnic groups (Thompson et al. 2018).

The prevalence of cigarette use among adults who identify with specific racial and ethnic groups has changed over time, according to data from NHIS (Figure 2.1). Table 2.4 provides NSDUH data from 2019 on the prevalence of cigarette use among adults across the seven racial and ethnic groups described previously in this chapter. The highest prevalence of ever use of cigarettes was among American Indian and Alaska Native adults (68.6%; 95% CI, 59.7–77.5), followed by White (68.1%; 95% CI, 67.1–69.0), multiple race (64.5%; 95% CI, 60.7–68.2), Hispanic (46.4%; 95% CI, 44.6–48.1), Black (45.2%; 95% CI, 43.1–47.3), Native Hawaiian and Pacific Islander (41.8%; 95% CI, 32.8–50.7), and Asian (32.3%; 95% CI, 28.9–35.8) adults.

Estimates by race and ethnicity from the 2019 NSDUH indicate that past-month use of cigarettes, defined as having smoked part or all of a cigarette during the 30 days prior to the interview, was generally lowest among adults 65 years of age and older (Table 2.5). Among Asian, Black, Hispanic, multiple race, or White adults, the prevalence of ever cigarette use increased between ages 18–25 and 26–49. Among Black, multiple race, and White adults, the prevalence of past-month cigarette use also increased significantly between ages 18–25 and 26–49.

The highest prevalence of past-month cigarette use was observed among American Indian and Alaska Native adults (30.7%; 95% CI, 23.7–37.7) and multiple race adults (30.6%; 95% CI, 26.7–34.5), followed by Black (20.6%; 95% CI, 18.8–22.3), White (19.4%; 95% CI, 18.6–20.1), Native Hawaiian and Pacific Islander (14.1%; 95% CI, 8.6–19.7), Hispanic (13.4%; 95% CI, 12.2–14.7), and Asian adults (8.0%; 95% CI, 6.3–9.7) (Table 2.4).

### Menthol Cigarette Use

Evidence reviews have concluded that, compared with nonmenthol cigarette use, menthol cigarette use is associated with a greater likelihood of dependence among young people who are experimenting with smoking and with decreased likelihood of cessation success among adults who are trying to quit (Tobacco Products Scientific Advisory Committee 2011; U.S. Food and Drug Administration [FDA] 2013a,b; Villanti et al. 2017; Federal Register 2022).

Table 2.3 Prevalence of ever use of cigarettes^a^ and electronic vapor products, current use^b^ of tobacco products, and quit attempts^c^ among high school students, by race, ethnicity,^d^ and sex; national Youth Risk Behavior Survey (YRBS) 2019, United States A. By race and ethnicity

A By race and ethnicity

Race and ethnicity | Ever use of cigarettes: % (95% CI) | Ever use of electronic vapor products: % (95% CI) | Current use of tobacco products: % (95% CI)
Race and ethnicity | Ever use of cigarettes: % (95% CI) | Ever use of electronic vapor products: % (95% CI) | Cigarettes | Cigars^e^ | Smokeless tobacco^f^ | Electronic vapor products^g^ | ≥2 tobacco products^h^ | Ever quit attempt: % (95% CI)
Total | 24.1 (21.3–27.0) | 50.1 (48.1–52.2) | 6.0 (5.0–7.2) | 5.7 (4.8–6.7) | 3.8 (3.2–4.6) | 32.7 (30.7–34.8) | 8.2 (7.0–9.5) | 47.6 (45.1–50.1)
American Indian and Alaska Native | 37.9 (25.0–52.8) | 57.9 (44.7–70.0) | 20.6 (10.8–35.9) | 14.9 (7.4–27.9) | 16.2 (7.0–33.2) | 47.3 (34.7–60.4) | 23.8 (13.4–38.5) | 48.5 (27.1–70.5)
Asian | 8.9 (6.7–11.8) | 24.9 (21.5–28.6) | 2.3 (1.2–4.3) | 1.0 (0.4–3.0) | 0.8 (0.3–1.9) | 13.0 (9.5–17.5) | 2.5 (1.3–4.8) | 43.1 (33.4–53.3)
Black | 14.2 (10.7–18.7) | 40.0 (37.2–42.7) | 3.3 (2.3–4.6) | 5.3 (4.1–6.8) | 2.8 (1.8–4.4) | 19.7 (16.9–22.8) | 4.8 (3.7–6.2) | 33.8 (26.2–42.4)
Hispanic | 26.1 (21.0–32.0) | 49.5 (47.0–52.1) | 6.0 (4.3–8.4) | 6.1 (4.7–8.0) | 3.1 (2.3–4.3) | 31.2 (28.6–33.8) | 7.9 (6.2–10.0) | 51.5 (46.0–56.9)
Multiple race | 30.6 (25.9–35.6) | 55.3 (48.6–61.8) | 8.0 (5.5–11.3) | 6.5 (4.4–9.6) | 3.8 (2.1–6.8) | 33.5 (28.1–39.4) | 9.2 (6.6–12.7) | 48.0 (38.2–57.9)
Native Hawaiian and Other Pacific Islander | 23.7 (13.4–38.4) | 58.7 (46.6–69.8) | 4.5 (1.2–15.2) | 8.6 (2.9–22.6) | 13.8 (5.0–32.9) | 38.8 (28.2–50.5) | 15.7 (6.4–33.9) | —^i^
White | 25.6 (22.2–29.4) | 54.7 (52.2–57.2) | 6.7 (5.3–8.4) | 5.9 (4.7–7.4) | 4.4 (3.3–5.7) | 38.3 (36.0–40.7) | 9.5 (7.8–11.5) | 48.4 (45.1–51.7)

B By race, ethnicity, and sex^j^

Race, ethnicity, and sex | Ever use of cigarettes: % (95% CI) | Ever use of electronic vapor products: % (95% CI) | Current use of tobacco products: % (95% CI)
Race, ethnicity, and sex | Ever use of cigarettes: % (95% CI) | Ever use of electronic vapor products: % (95% CI) | Cigarettes | Cigars^e^ | Smokeless tobacco^f^ | Electronic vapor products^g^ | ≥2 tobacco products^h^ | Ever quit attempt: % (95% CI)
Total
Male | 25.3 (22.1–28.8) | 49.6 (47.3–51.9) | 6.9 (5.7–8.4) | 7.4 (6.4–8.6) | 5.8 (4.7–7.1) | 32.0 (29.7–34.3) | 10.4 (9.0–11.9) | 45.6 (42.8–48.6)
Female | 22.9 (20.1–26.1) | 50.7 (48.2–53.2) | 4.9 (3.8–6.4) | 3.8 (2.8–5.1) | 1.6 (1.2–2.1) | 33.5 (30.9–36.1) | 5.8 (4.5–7.5) | 50.0 (45.7–54.3)
American Indian and Alaska Native
Male | 39.6 (23.8–57.9) | 54.2 (38.5–69.1) | 22.3 (10.5–41.3) | 20.5 (9.2–39.5) | 23.3 (10.3–44.5) | 48.7 (35.0–62.5) | 26.7 (14.0–44.8) | —^i^
Female | 37.2 (19.1–59.8) | 63.7 (43.4–80.1) | 15.7 (5.1–39.2) | 7.8 (2.4–22.9) | 3.4 (0.6–17.8) | 47.3 (28.5–66.8) | 17.4 (6.4–39.5 | —^i^
Asian
Male | 10.4 (7.6–14.3) | 25.1 (19.3–32.0) | 3.6 (1.5–8.2) | 1.9 (0.6–6.0) | 0.9 (0.3–2.3) | 13.8 (9.4–20.0) | 3.8 (1.8–8.2) | 48.3 (34.7–62.2)
Female | 7.4 (3.7–14.0) | 24.7 (20.2–29.7) | 1.0 (0.3–3.3) | 0.2 (0.0–1.0) | 0.7 (0.2–1.9) | 12.1 (8.4–17.2) | 1.2 (0.6–2.4) | 36.7 (21.1–55.7)
Black
Male | 15.8 (11.1–22.1) | 40.8 (36.4–45.2) | 4.2 (2.7–6.6) | 6.4 (4.6–8.9) | 3.7 (2.2–6.2) | 21.5 (18.2–25.1) | 6.0 (4.3–8.4) | 39.9 (31.4–49.1)
Female | 12.3 (9.2–16.3) | 39.0 (34.6–43.5) | 2.0 (1.0–4.0) | 3.8 (2.3–6.1) | 1.7 (0.8–3.8) | 17.7 (14.4–21.4) | 3.2 (1.9–5.2) | 25.6 (15.3–39.5)
Hispanic
Male | 28.1 (20.4–37.4) | 48.5 (45.2–51.8) | 7.8 (4.8–12.5) | 7.3 (5.4–9.9) | 3.4 (2.2–5.1) | 29.2 (25.9–32.9) | 9.7 (7.0–13.4) | 49.3 (43.6–55.1)
Female | 24.4 (20.7–28.4) | 50.5 (46.3–54.8) | 4.3 (3.1–6.0) | 4.9 (3.3–6.9) | 2.9 (1.9–4.3) | 33.0 (29.1–37.1) | 6.1 (4.5–8.1) | 53.4 (45.1–61.6)
Multiple race
Male | 29.3 (22.3–37.3) | 52.9 (44.3–61.4) | 8.6 (5.6–13.1) | 8.5 (4.8–14.5) | 6.2 (3.2–11.7) | 32.4 (25.6–40.1) | 11.9 (8.2–17.0) | 49.9 (34.8–64.9)
Female | 31.8 (24.6–40.0) | 57.6 (48.7–66.1) | 7.3 (4.2–12.4) | 4.8 (2.5–9.1) | 1.7 (0.7–4.4) | 34.7 (28.3–41.7) | 6.8 (3.9–11.5) | 46.5 (30.1–63.8)
White
Male | 26.9 (23.8–30.3) | 54.4 (51.5–57.3) | 7.4 (6.1–8.9) | 8.1 (6.6–10.0) | 7.6 (5.7–10.0) | 37.7 (34.9–10.6) | 12.3 (10.4–14.4) | 45.1 (41.4–48.9)
Female | 24.4 (20.1–29.2) | 55.1 (52.0–58.1) | 6.0 (4.1–8.6) | 3.5 (2.3–5.2) | 0.9 (0.6–1.5) | 38.9 (35.9–12.0) | 6.6 (4.6–9.4) | 52.3 (46.9–57.7)

Source: YRBS, Centers for Disease Control and Prevention, public use data, 2019; CDC (n.d.a).

Notes: CI = confidence interval.

a At least one or two puffs.

b On at least 1 day during the 30 days before the survey.

c Includes ever quit attempt of cigarettes, cigars, smokeless tobacco, shisha or hookah tobacco, and electronic vapor products during the 12 months before the survey among high school students who used any tobacco products during the 12 months before the survey.

d All categories except Hispanic are considered non-Hispanic or Latino.

e Includes use of cigars, cigarillos, or little cigars on at least 1 day during the 30 days before the survey.

f Includes use of chewing tobacco, snuff, dip, snus, or dissolvable tobacco products—such as Redman, Levi Garrett, Beechnut, Skoal, Skoal Bandits, Copenhagen, Camel Snus, Marlboro Snus, General Snus, Ariva, Stonewall, or Camel Orbs—not counting any electronic vapor products on at least 1 day during the 30 days before the survey.

g Includes use of e-cigarettes, vapes, vape pens, e-cigars, e-hookahs, hookah pens, and mods (e.g., JUUL, Vuse, MarkTen, and blu) on at least 1 day during the 30 days before the survey.

h Percentage of students who used two or more of the following tobacco products: cigarettes, cigars (cigars, cigarillos, or little cigars), electronic vapor products, or smokeless tobacco on 1 or more days during the 30 days before the survey.

i Data are suppressed.

j Data for Native Hawaiian and Other Pacific Islander by sex are suppressed due to small sample sizes.

Table 2.4 Prevalence of ever use of cigarettes, past-month use of tobacco products, and cigarette smoking cessation among adults, 18 years of age and older, by race and ethnicity; National Survey on Drug Use and Health (NSDUH) 2019, United States

Race and ethnicity | Ever use of cigarettes: % (95% CI) | Past-month use of tobacco products: % (95% CI) | | | | | | Cigarette smoking cessation:^a^ % (95% CI)
Race and ethnicity | Ever use of cigarettes: % (95% CI) | Any tobacco product | Cigarettes | Cigars | Smokeless tobacco | Pipes | ≥2 tobacco products^b^ | Never quit or quit for ≤30 days^c^ | Quit for >30 days but <1 year^d^ | Quit for 1 year or more^e^
American Indian and Alaska Native | 68.6 (59.7–77.5) | 36.4 (29.0–43.8) | 30.7 (23.7–37.7) | 4.6 (2.8–6.4) | 7.1 (3.5–10.6) | —^f^ | 6.6 (4.3–9.0) | 45.0 (34.6–55.3) | —^f^ | 42.8 (31.6–54.1
Asian | 32.3 (28.9–35.8) | 10.2 (8.2–12.2) | 8.0 (6.3–9.7) | 1.4 (0.8–2.0) | 1.2 (0.5–2.0) | —^f^ | 0.6 (0.3–0.9) | 24.9 (20.5–29.4) | 10.3 (6.9–13.6) | 64.8 (59.3–70.3)
Black | 45.2 (43.1–47.3) | 25.8 (23.9–27.6) | 20.6 (18.8–22.3) | 8.6 (7.6–9.6) | 1.3 (0.9–1.8) | 0.7 (0.4–1.0) | 4.8 (4.0–5.6) | 46.0 (42.7–49.2) | 5.3 (4.1–6.5) | 48.7 (45.6–51.9)
Native Hawaiian and Pacific Islander | 41.8 (32.8–50.7) | 21.8 (14.6–29.0) | 14.1 (8.6–19.7) | —^f^ | —^f^ | —^f^ | —^f^ | 33.9 (21.7–46.0) | 12.7 (5.8–19.6) | 53.5 (39.1–67.9)
Hispanic | 46.4 (44.6–48.1) | 15.6 (14.3–17.0) | 13.4 (12.2–14.7) | 3.2 (2.7–3.8) | 0.9 (0.6–1.1) | 0.5 (0.3–0.7) | 2.2 (1.8–2.6) | 29.2 (26.5–31.9) | 9.0 (7.7–10.3) | 61.8 (58.9–64.6)
Multiple race | 64.5 (60.7–68.2) | 34.6 (30.5–38.6) | 30.6 (26.7–34.5) | 6.9 (4.6–9.2) | 3.9 (2.0–5.8) | 3.1 (1.7–4.6) | 7.7 (5.1–10.3) | 47.5 (42.5–52.5) | 6.6 (3.9–9.3) | 45.9 (40.5–51.2)
White | 68.1 (67.1–69.0) | 24.8 (24.0–25.6) | 19.4 (18.6–20.1) | 4.3 (4.0–4.7) | 4.5 (4.1–4.8) | 0.8 (0.6–1.0) | 3.6 (3.3–3.9) | 28.6 (27.5–29.7) | 5.4 (5.0–5.8) | 66.0 (64.8–67.2)

Source: NSDUH, Substance Abuse and Mental Health Services Administration, public use data, 2019.

Notes:CI = confidence interval.

a Cigarette smoking cessation estimates were calculated among people who had ever smoked cigarettes.

b Any combination of more than one tobacco product (cigarettes, cigars, smokeless tobacco, or pipes).

c Among people who had ever smoked cigarettes, respondent answered “Within the past 30 days” to the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

d Among people who had ever smoked cigarettes, respondent answered “More than 30 days ago but within the past 12 months.” To the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

e Among people who had ever smoked cigarettes, respondent answered “More than 12 months ago but within the past 3 years” or “More than 3 years ago” to the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

f Unstable estimate is not presented because of a relative standard error >0.3 or number of unweighted denominators <50.

Table 2.5 Prevalence of ever use of cigarettes, past-month use of tobacco products, and smoking cessation among adults, 18 years of age and older, by race and ethnicity and age (in years); National Survey on Drug Use and Health (NSDUH) 2019, United States

Race, ethnicity, and age (in years) | Ever use of cigarettes: % (95% CI) | Past-month use of tobacco products: % (95% CI) | | | | | Cigarette smoking cessation:^a^ % (95% CI)
Race, ethnicity, and age (in years) | Ever use of cigarettes: % (95% CI) | Cigarettes | Cigars | Smokeless tobacco | Pipes | ≥2 tobacco products^b^ | Never quit or quit for ≤30 days^c^ | Quit for >30 days but <1 year^d^ | Quit for 1 year or more^e^
American Indian and Alaska Native
18–25 | 65.0 (56.1–74.0) | 29.1 (19.3–39.0) | —^f^ | 10.9 (6.0–15.8) | —^f^ | 9.6 (4.3–14.9) | 44.8 (32.8–56.7) | 20.6 (8.3–32.8) | 34.6 (24.1–45.2)
26–49 | 79.6 (71.8–87.5) | 43.3 (34.3–52.2) | 7.4 (4.3–10.5) | 9.5 (4.0–15.0) | —^f^ | 11.1 (6.3–16.0) | 54.8 (45.2–64.4) | —^f^ | 42.6 (33.2–52.1)
50–64 | 67.0 (50.2–83.8) | 32.9 (17.5–48.4) | —^f^ | —^f^ | —^f^ | —^f^ | 49.2 (28.5–69.8) | —^f^ | —^f^
≥65 | —^f^ | —^f^ | N/A | N/A | N/A | N/A | —^f^ | —^f^ | —^f^
Asian
18–25 | 27.3 (23.0–31.5) | 9.3 (7.2–11.4) | 2.2 (0.9–3.6) | —^f^ | —^f^ | —^f^ | 35.2 (29.1–41.3) | 22.6 (15.6–29.6) | 42.2 (33.5–51.0)
26–49 | 37.1 (32.4–41.7) | 9.4 (7.4–11.4) | 1.5 (0.6–2.3) | —^f^ | —^f^ | —^f^ | 25.4 (20.8–29.9) | 11.2 (7.3–15.1) | 63.4 (58.1–68.7)
50–64 | 29.9 (19.5–40.3) | —^f^ | —^f^ | —^f^ | —^f^ | N/A | —^f^ | —^f^ | —^f^
≥65 | 25.0 (14.8–35.1) | —^f^ | —^f^ | N/A | N/A | N/A | —^f^ | N/A | —^f^
Black
18–25 | 27.2 (24.9–29.4) | 12.3 (10.5–14.0) | 12.2 (10.2–14.2) | 1.5 (0.7–2.2) | —^f^ | 4.7 (3.3–6.1) | 46.5 (41.0–52.0) | 13.0 (9.2–16.9) | 40.5 (35.0–45.9)
26–49 | 47.4 (45.3–49.6) | 24.4 (22.7–26.0) | 11.1 (9.5–12.8) | 1.1 (0.6–1.6) | 0.7 (0.4–1.1) | 6.0 (4.8–7.1) | 51.6 (48.3–55.0) | 5.7 (4.1–7.4) | 42.6 (39.6–45.6)
50–64 | 49.5 (43.8–55.2) | 25.1 (20.5–29.6) | 5.3 (3.0–7.6) | —^f^ | —^f^ | 4.5 (2.4–6.6) | 51.2 (45.1–57.3) | —^f^ | 45.3 (38.9–51.7)
≥65 | 49.6 (44.3–54.9) | 11.5 (7.8–15.2) | 3.2 (1.3–5.1) | —^f^ | —^f^ | —^f^ | 23.2 (16.1–30.2) | —^f^ | 74.0 (66.7–81.3)
Native Hawaiian and Pacific Islander
18–25 | 34.9 (20.3–49.5) | —^f^ | —^f^ | —^f^ | —^f^ | —^f^ | —^f^ | —^f^ | —^f^
26–49 | 50.3 (38.2–62.4) | 13.7 (6.0–21.3) | —^f^ | —^f^ | —^f^ | —^f^ | 27.2 (12.6–41.8) | —^f^ | 62.4 (46.7–78.2)
50–64 | —^f^ | —^f^ | N/A | N/A | —^f^ | —^f^ | —^f^ | —^f^ | —^f^
≥65 | —^f^ | —^f^ | N/A | N/A | N/A | N/A | —^f^ | N/A | —^f^
Hispanic
18–25 | 38.8 (36.5–41.1) | 13.8 (12.0–15.7) | 5.2 (4.2–6.2) | 1.8 (1.1–2.4) | 0.8 (0.4–1.3) | 3.9 (3.0–4.8) | 36.3 (31.6–41.1) | 18.6 (14.8–22.4) | 45.1 (40.4–49.7)
26–49 | 50.3 (48.0–52.6) | 16.1 (14.5–17.7) | 3.8 (3.1–4.6) | 1.0 (0.6–1.3) | 0.7 (0.3–1.1) | 2.5 (1.9–3.0) | 32.3 (29.6–34.9) | 8.4 (6.7–10.2) | 59.3 (56.1–62.5)
50–64 | 47.1 (42.6–51.7) | 11.1 (7.4–14.7) | —^f^ | —^f^ | —^f^ | —^f^ | 23.5 (15.6–31.4) | —^f^ | 71.5 (63.4–79.7)
≥65 | 40.0 (33.4–46.7) | 5.4 (2.5–8.2) | N/A | —^f^ | —^f^ | —^f^ | 13.4 (5.5–21.3) | —^f^ | 80.7 (71.0–90.4)
Multiple race
18–25 | 43.6 (38.4–48.8) | 20.1 (15.5–24.6) | 8.6 (6.0–11.3) | 5.4 (2.7–8.0) | —^f^ | 8.9 (6.0–11.8) | 46.6 (38.5–54.7) | 13.7 (7.6–19.8) | 39.7 (29.6–49.8)
26–49 | 71.0 (66.1–75.8) | 32.6 (27.4–37.7) | 6.6 (4.0–9.2) | —^f^ | 2.4 (1.4–3.5) | 6.2 (4.0–8.4) | 45.8 (39.9–51.7) | 5.9 (2.6–9.2) | 48.3 (42.1–54.4)
50–64 | 72.5 (62.1–82.9) | 41.3 (30.7–51.8) | —^f^ | —^f^ | —^f^ | —^f^ | 56.9 (43.3–70.6) | —^f^ | 39.7 (26.4–52.9)
≥65 | 64.4 (51.0–77.8) | 25.6 (11.8–39.5) | —^f^ | —^f^ | —^f^ | —^f^ | —^f^ | —^f^ | 53.3 (33.4–73.3)
White
18–25 | 51.1 (49.4–52.8) | 21.4 (20.1–22.6) | 8.0 (7.3–8.8) | 7.5 (6.6–8.3) | 1.6 (1.3–2.0) | 7.7 (6.8–8.5) | 42.4 (40.3–44.5) | 19.6 (18.0–21.3) | 38.0 (35.9–40.0)
26–49 | 71.4 (70.3–72.5) | 25.3 (24.3–26.2) | 4.8 (4.4–5.3) | 6.5 (6.0–7.0) | 0.7 (0.5–0.9) | 4.6 (4.1–5.1) | 35.5 (34.1–36.9) | 6.5 (6.0–7.1) | 58.0 (56.7–59.3)
50–64 | 71.7 (70.1–73.4) | 20.7 (19.2–22.3) | 4.3 (3.4–5.2) | 3.6 (2.7–4.4) | 0.8 (0.3–1.2) | 2.7 (2.1–3.3) | 29.1 (26.9–31.3) | 2.8 (2.0–3.6) | 68.1 (65.7–70.5)
≥65 | 67.1 (64.5–69.6) | 8.5 (7.3–9.7) | 2.0 (1.4–2.6) | 1.2 (0.8–1.5) | 0.5 (0.2–0.8) | 1.1 (0.6–1.6) | 12.8 (11.0–14.6) | 1.8 (1.2–2.4) | 85.4 (83.5–87.2)

Source: NSDUH, Substance Abuse and Mental Health Services Administration, public use data, 2019.

Notes: CI = confidence interval; N/A = not available.

a Cigarette smoking cessation estimates were calculated among those who responded “Yes” to “Have you ever smoked part or all of a cigarette?”

b Any combination of more than one tobacco product (cigarettes, cigars, smokeless tobacco, or pipes).

c Among people who had ever smoked cigarettes, respondent answered “Within the past 30 days” to the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

d Among people who had ever smoked cigarettes, respondent answered “More than 30 days ago but within the past 12 months.” To the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

e Among people who had ever smoked cigarettes, respondent answered “More than 12 months ago but within the past 3 years” or “More than 3 years ago” to the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

f Unstable estimate is not presented because of a relative standard error >0.3 or number of unweighted denominators <50.

Figure 2.1 Trends in the prevalence of current cigarette smoking^a^ a For NHIS survey years 1965–1991, people who currently smoked included adults who reported having smoked 100 or more cigarettes in their lifetimes and specified that they currently smoked. Since 1992, people who currently smoked included adults who reported having smoked at least 100 cigarettes in their lifetimes and specified that they currently smoked “every day” or “some days.” among adults, 18 years of age and older, by race and ethnicity;^b^ b All other categories, not necessarily Hispanic (NHIS Survey did not code for Hispanic as a separate demographic from 1965 to 1974). ^,c^ c Beginning with the 1999 NHIS, “Asian American and Pacific Islander” was assessed separately as “Asian” and “Native Hawaiian and Other Pacific Islander.” For purposes of trends, these categories are combined here. National Health Interview Survey (NHIS) 1965–2021,^d^ d For the “Overall” category, data for White, non-Hispanic; Black, non-Hispanic, and Hispanic people were not reported for 1966–1969, 1971–1973, 1975–1977, 1979, 1981, 1982, 1984, 1986, 1988, 1989, and 1996. For the specific races/ethnicities, data were not reported for people who were American Indian and Alaska Native and Asian American and Pacific Islander for 1965–1977, 1979, 1981, 1982, 1984, 1986, 1988, 1989, and 1996. ^,e^ e The NHIS underwent a redesign in 2019. Because of the changes in weighting and design methodology, direct comparisons between estimates beginning in 2019 and earlier years should be made with caution because the effects of these changes have not been fully evaluated yet. This change is represented by a break in the trend lines between 2018 and 2019. United States

The prevalence of cigarette smoking among adults decreased overall and within specific racialized and ethnic groups from 1965 to 2021: Overall, from 42% to 12%; among White, non-Hispanic people, from 42% to 13%; among Black, non-Hispanic people, from 46% to 12%; among Hispanic people, from 40% to 8%; among American Indian and Alaska Native people, from 45% (in 1978) to 19%; among Asian American and Pacific Islander people, from 24% (in 1978) to 5%; and among Other racial and ethnic groups, from 27% (in 1978) to 15%.

Source: NHIS, National Center for Health Statistics, public use data, 1965–2021.

Several studies published since 2009 have also documented the higher prevalence of menthol cigarette use among Black people who smoke compared with White or Hispanic people who smoke (Cubbin et al. 2010; Lawrence et al. 2010; Rock et al. 2010; Jones et al. 2013; Giovino et al. 2015; Villanti et al. 2016; Seaman et al. 2022). Table 2.6 presents the prevalence of menthol cigarette use among people who had smoked cigarettes during the past month by racial and ethnic group. Estimates from 2017–2019 NSDUH data show that the prevalence of menthol cigarette use was highest among Black people who smoke cigarettes (88.1%; 95% CI, 86.4–89.6), followed by Native Hawaiian and Pacific Islander (73.5%; 95% CI, 59.4–89.6), Hispanic (50.0%; 95% CI, 47.6–52.4), multiple race (48.2%; 95% CI, 43.3–53.1), Asian (45.0%; 95% CI, 39.0–51.0), American Indian and Alaska Native (34.2%; 95% CI, 29.3–39.5), and White people who smoke (31.4%; 95% CI, 30.4–32.3).

The prevalence of menthol cigarette use was also higher among women (46.2%; 95% CI, 44.9–47.6) versus men (38.7%; 95% CI, 37.5–39.8); among people who identify as lesbian or gay (50.8%; 95% CI, 45.2–56.5) or bisexual (51.8%; 95% CI, 49.1–54.5) versus those who identify as heterosexual (41.0%; 95% CI, 40.0–42.0); among people with household incomes less than $75,000 (<$10,000–$29,999: 48.4%; 95% CI, 46.4–50.4; $30,000–$74,999: 43.4%; 95% CI, 42.1–44.7) versus people with household incomes of $75,000 or more (39.0%; 95% CI, 36.8–41.2); and among people reporting symptoms of past-month serious psychological distress (50.5%; 95% CI, 47.9–53.0) versus people not reporting such symptoms (40.8%; 95% CI, 39.8–41.7). These patterns were generally consistent across young adults (18–25 years of age) and older adults (26 years of age and older).

Table 2.6 Prevalence of menthol cigarette use^a^ among people who smoked during the past month, by age group, gender, sexual orientation, race and ethnicity, household income, and past-month serious psychological distress; National Survey on Drug Use and Health (NSDUH) 2017–2019, United States

Characteristics | Tatal: % (95% CI) | Youth (12–17 years of age): % (95% CI) | Young adults (18–25 years of age): % (95% CI) | Adults (26 years of age and older): % (95% CI)
Overall | 42.1 (41.2–43.0) | 54.3 (50.3–58.3) | 52.4 (51.1–53.8) | 40.2 (39.2–41.2)
Gender
Male | 38.7 (37.5–39.8) | 52.4 (46.6–58.2) | 47.4 (45.5–49.2) | 36.9 (35.6–38.2)
Female | 46.2 (44.9–47.6) | 56.6 (50.9–62.1) | 59.4 (57.4–61.5) | 44.1 (42.5–45.7)
Sexual orientation
Heterosexual | 41.0 (40.0–42.0) | N/A | 51.3 (49.8–52.9) | 39.4 (38.4–40.5)
Lesbian/gay | 50.8 (45.2–56.5) | N/A | 58.1 (49.8–65.9) | 49.1 (42.7–55.5)
Bisexual | 51.8 (49.1–54.5) | N/A | 57.9 (54.0–61.7) | 48.7 (45.3–52.2)
Race and ethnicity
American Indian and Alaska Native | 34.2 (29.3–39.5) | —^b^ | 43.7 (31.6–56.5) | 32.2 (26.7–38.3)
Asian | 45.0 (39.0–51.0) | —^b^ | 51.8 (43.0–60.5) | 43.6 (36.8–50.6)
Black | 88.1 (86.4–89.6) | —^b^ | 88.8 (86.2–90.9) | 88.1 (86.2–89.7)
Native Hawaiian and Pacific Islander | 73.5 (59.4–84.1) | —^b^ | 76.0 (55.1–89.0) | 73.5 (56.9–85.4)
Hispanic | 50.0 (47.6–52.4) | 60.6 (50.4–69.8) | 60.5 (56.7–64.2) | 47.3 (44.4–50.2)
Multiple race | 48.2 (43.3–53.1) | 38.3 (25.4–53.1) | 47.1 (40.8–53.5) | 48.7 (42.9–54.5)
White | 31.4 (30.4–32.3) | 52.7 (48.1–57.2) | 44.6 (43.0–46.2) | 28.9 (27.8–30.1)
Household income
<$10,000–$29,999 | 48.4 (46.4–50.4) | 63.0 (54.3–70.9) | 51.3 (48.9–53.7) | 47.6 (45.3–49.9)
$30,000–$74,999 | 43.4 (42.1–44.7) | 52.6 (45.4–59.8) | 56.1 (53.9–58.3) | 41.3 (39.8–42.8)
$75,000 or more | 39.0 (36.8–41.2) | 44.2 (35.4–53.5) | 52.2 (47.9–56.5) | 37.0 (34.6–39.5)
Past-month serious psychological distress ^c^
Yes | 50.5 (47.9–53.0) | N/A | 56.5 (53.4–59.5) | 48.5 (45.3–51.7)
No | 40.8 (39.8–41.7) | N/A | 51.3 (49.8–52.8) | 39.2 (38.2–40.2)

Source: NSDUH, National Survey on Drug Use and Health, 2017–2019.

Notes: CI = confidence intervals. N/A = Data unavailable.

a Includes people who smoked cigarettes during the past month and who indicated having smoked a menthol cigarette or a brand of Kool or menthol.

b Data were statistically unreliable because of an unweighted denominator <50 or a relative standard error >30%.

c Serious psychological distress was defined using the Kessler-6 measure. Respondents were rated on a Likert scale for how frequently they experienced the following symptoms of psychological distress during the past 30 days: (1) nervousness, (2) hopelessness, (3) feeling restless or fidgety, (4) feeling so depressed that nothing could cheer them up, (5) feeling that everything was an effort, and (6) feeling worthless. Responses were coded as follows: ‘‘all of the time’’ was coded as 4; ‘‘most of the time’’ as 3; ‘‘some of the time’’ as 2; ‘‘a little of the time’’ as 1; and ‘‘none of the time’’ as 0. Response codes 0–4 were summed to yield a score range of 0–24. Serious psychological

The higher prevalence of menthol cigarette use among certain populations has implications for health disparities for two primary reasons. First, menthol in tobacco products is positively associated with increased tobacco product initiation and progression to regular tobacco use (Nonnemaker et al. 2013; Villanti et al. 2019, 2021), which could increase exposure to cigarette smoking and its harms (USDHHS 2014). Second, among some minoritized racial and ethnic populations, tobacco cessation is lower among people who smoke menthol cigarettes than among people who smoke nonmenthol cigarettes (Stahre et al. 2010; Delnevo et al. 2011b; Smith et al. 2020a).

Greater progression to regular cigarette use and reduced successful quitting means that group differences in menthol cigarette use could serve to maintain or worsen disparities in current cigarette use overall. Chapter 3 of this report details the factors that may influence the use of flavored tobacco products, including menthol, by certain groups of people and how this use influences tobacco-related health disparities along the tobacco use continuum.

### Patterns of Frequency and Quantity of Cigarette Use

Understanding racial and ethnic differences in cigarette use is complicated by differences in the frequency and quantity of use by populations. Historically, nondaily cigarette use has been more common among some racial and ethnic groups (NCI 2017; Wang et al. 2018) compared with White people. In particular, Black, Asian and Pacific Islander, and Hispanic people who smoke were found to be more likely to smoke intermittently and to consume fewer cigarettes on days in which they smoked than White people (Trinidad et al. 2011). Compared with never using cigarettes, nondaily cigarette use is associated with a higher risk of death, including death from cancer, heart disease, and respiratory disease (Inoue-Choi et al. 2019, 2020).

NSDUH data from 2019 on adults 18 years of age and older indicate that, among American Indian and Alaska Native people, 13.6% of men and 11.2% of women smoked cigarettes nondaily in the past month. The prevalence of nondaily cigarette use was next highest among Black (13.3% of men, 9.0% of women), multiple race (10.9% of men, 10.5% of women), Hispanic (10.7% of men, 5.8% of women), Asian (7.9% of men, 2.5% of women), White (7.2% of men, 6.0% of women), and Native Hawaiian and Pacific Islander (4.8% of men, 6.9% of women) people (NSDUH, public use data, 2019).

### Patterns of Smoking Cessation

Investigations into racial and ethnic differences in cessation suggest that, compared with White people, Black people who smoke make more quit attempts but are less successful at long-term quitting (Kulak et al. 2016). Data from the NSDUH in 2019 (Table 2.4) align with this pattern. The prevalence of long-term quitting (1 year or more) among adults who had ever smoked cigarettes was lower among American Indian and Alaska Native (42.8%; 95% CI, 31.6–54.1), Black (48.7%; 95% CI, 45.6–51.9), and multiple race (45.9%; 95% CI, 40.5–51.2) adults than Hispanic (61.8%; 95% CI, 58.9–64.6), Asian (64.8%; 95% CI, 59.3–70.3), and White (66.0%; 95% CI, 64.8–67.2) adults, as indicated by nonoverlapping confidence intervals. This finding may be related, in part, to the higher prevalence of nondaily smoking among some racial and ethnic groups compared with White people (Wang et al. 2018). Additionally, some studies have reported a lower likelihood of Black and Hispanic people who smoke cigarettes being asked about tobacco use in a healthcare visit, being advised to quit, or having used tobacco cessation aids in a past-year quit attempt compared with White people who smoke (Cokkinides et al. 2008; Babb et al. 2020).

Further, the use of menthol cigarettes can decrease the likelihood of cessation success among adults who are trying to quit. Evidence suggests that menthol in cigarettes is associated with a reduced likelihood of successful quitting overall and particularly among people in minoritized racial and ethnic populations who smoke cigarettes (Gundersen et al. 2009; Stahre et al. 2010; Delnevo et al. 2011b; Levy et al. 2011; Smith et al. 2020a; Mills et al. 2021). Additionally, Smith and colleagues (2014b) found that Black women who smoke menthol cigarettes may have significantly lower cessation outcomes than White women who smoke menthol cigarettes.

### Patterns of Any Tobacco Product Use

#### Youth

Based on data from the 2020 NYTS, an estimated 23.6% (95% CI, 21.1–26.4) of U.S. high school students reported current use of any tobacco product, defined as having used e-cigarettes, cigarettes, cigars (cigars, cigarillos, and little cigars), smokeless tobacco (chewing tobacco, snuff, dip, snus, and dissolvable tobacco products), hookahs, pipe tobacco, bidis (small brown cigarettes wrapped in a leaf), or heated tobacco products on at least 1 day during the past 30 days (Gentzke et al. 2020). Figure 2.2 (Part A) presents trends in the current use of any tobacco product during 2011–2020 among U.S. high school students by race and ethnicity. In 2020, current use of any tobacco product was higher among White high school students (25.9%; 95% CI, 23.0–29.2) than Black students (18.4%; 95% CI, 15.5–21.8) and students of other races (15.7%; 95% CI, 12.1–20.2), while Hispanic students (23.3%; 95% CI, 19.4–27.7) had a similar prevalence of current use of any tobacco product as all other racial and ethnic groups.

#### Adults

Tables 2.4, 2.6, and 2.7 provide NSDUH data on the past-month prevalence of use of cigarettes, cigars, smokeless tobacco, pipes, and any tobacco product among adults (18 years and older) for 2019. Use of any tobacco product, defined as use of cigarettes, cigars, smokeless tobacco, and pipe tobacco during the past 30 days, was higher among American Indian and Alaska Native (36.4%; 95% CI, 29.0–43.8) and multiple race (34.6%; 95% CI, 30.5–38.6) adults than Black (25.8%; 95% CI, 23.9–27.6), White (24.8%; 95% CI, 24.0–25.6), Native Hawaiian and Pacific Islander (21.8%; 95% CI, 14.6–29.0), Hispanic (15.6%; 95% CI, 14.3–17.0), and Asian (10.2%; 95% CI, 8.2–12.2) adults (Table 2.4).

Table 2.7 Prevalence of ever use of cigarettes, past-month use of tobacco products, and smoking cessation among adults, 18 years of age and older, by race and ethnicity and sex; National Survey on Drug Use and Health (NSDUH) 2019, United States

Race and ethnicity and sex | Ever use of cigarettes: % (95% CI) | Past-month use of tobacco products: % (95% CI) | | | | | Smoking cessation: % (95% CI)^a^
Race and ethnicity and sex | Ever use of cigarettes: % (95% CI) | Cigarettes | Cigars | Smokeless tobacco | Pipes | ≥2 tobacco products^b^ | Never quit or quit for ≤30 days^c^ | Quit for >30 days but <1 year^d^ | Quit for 1 year or more^e^
American Indian and Alaska Native
Female | 62.3 (49.4–-75.1) | 30.9 (21.0–40.8) | —^f^ | —^f^ | —^f^ | —^f^ | 49.6 (34.7–64.5) | —^f^ | 44.6 (29.2–60.1)
Male | 76.4 (66.5–86.4) | 30.4 (20.8–40.0) | 7.5 (4.1–10.8) | 13.4 (5.7–21.2) | —^f^ | 9.6 (5.6–13.6) | 40.3 (25.7–54.9) | —^f^ | 41.0 (24.7–57.2)
Asian
Female | 18.9 (14.5–23.3) | 4.6 (3.0–6.2) | —^f^ | —^f^ | —^f^ | —^f^ | 24.4 (17.4–31.3) | 12.8 (7.0–18.7) | 62.8 (54.0–71.6)
Male | 47.8 (43.0–52.6) | 12.0 (9.3–14.7) | 2.7 (1.4–4.0) | —^f^ | —^f^ | —^f^ | 25.2 (19.9–30.5) | 9.1 (5.0–13.1) | 65.7 (59.8–71.7)
Black
Female | 41.3 (38.5–44.0) | 17.1 (15.2–19.0) | 5.4 (4.5–6.4) | 0.7 (0.3–1.1) | —^f^ | 2.6 (2.0–3.1) | 41.9 (37.8–46.0) | 3.9 (2.7–5.2) | 54.2 (49.7–58.6)
Male | 49.9 (46.8–53.0) | 24.7 (22.1–27.3) | 12.4 (10.7–14.0) | 2.1 (1.2–3.0) | 1.1 (0.6–1.6) | 7.5 (6.1–9.0) | 50.1 (45.8–54.3) | 6.6 (4.7–8.6) | 43.3 (39.2–47.4)
Native Hawaiian and Pacific Islander
Female | 40.7 (28.0–53.3) | 11.5 (4.9–18.1) | —^f^ | —^f^ | —^f^ | —^f^ | —^f^ | —^f^ | —^f^
Male | 42.6 (30.0–55.2) | 16.2 (6.7–25.6) | —^f^ | —^f^ | —^f^ | —^f^ | 37.9 (19.2–56.6) | —^f^ | —^f^
Hispanic
Female | 37.8 (35.3–40.2) | 9.3 (7.8–10.8) | 1.3 (0.9–1.7) | —^f^ | —^f^ | 1.0 (0.6–1.4) | 24.6 (20.9–28.3) | 9.3 (7.2–11.3) | 66.1 (61.8–70.4)
Male | 55.0 (52.7–57.4) | 17.6 (15.8–19.5) | 5.2 (4.1–6.3) | 1.4 (0.9–1.8) | 0.8 (0.5–1.1) | 3.4 (2.7–4.2) | 32.4 (29.1–35.8) | 8.9 (6.9–10.8) | 58.7 (55.1–62.3)
Multiple race
Female | 62.4 (56.7–68.1) | 26.8 (21.2–32.3) | 4.1 (2.2–6.0) | —^f^ | —^f^ | —^f^ | 43.0 (35.2–50.7) | —^f^ | 50.1 (42.4–57.8)
Male | 66.7 (61.0–72.4) | 34.8 (29.1–40.4) | 10.0 (5.9–14.1) | 7.5 (3.9–11.1) | 4.7 (2.7–6.6) | 12.3 (7.9–16.7) | 52.1 (45.0–59.2) | 6.3 (3.3–9.3) | 41.6 (33.9–49.2)
White
Female | 65.2 (63.7–66.7) | 18.6 (17.5–19.7) | 1.6 (1.3–1.9) | 0.7 (0.5–0.8) | 0.3 (0.2–0.5) | 1.4 (1.2–1.7) | 28.6 (27.1–30.1) | 4.8 (4.3–5.4) | 66.6 (65.0–68.1)
Male | 71.1 (70.1–72.2) | 20.2 (19.3–21.1) | 7.2 (6.6–7.8) | 8.5 (7.8–9.2) | 1.3 (1.0–1.6) | 5.8 (5.2–6.4) | 28.7 (27.3–30.0) | 5.9 (5.3–6.6) | 65.4 (64.0–66.8)

Source: NSDUH, Substance Abuse and Mental Health Services Administration, public use data, 2019.

Notes: CI = confidence interval.

a Cigarette smoking cessation estimates were calculated among those who responded “Yes” to “Have you ever smoked part or all of a cigarette?”

b Any combination of more than one tobacco product (cigarettes, cigars, smokeless tobacco, or pipes).

c Among people who had ever smoked cigarettes, respondent answered “Within the past 30 days” to the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

d Among people who had ever smoked cigarettes, respondent answered “More than 30 days ago but within the past 12 months.” To the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

e Among people who had ever smoked cigarettes, respondent answered “More than 12 months ago but within the past 3 years” or “More than 3 years ago” to the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

f Unstable estimate is not presented because of a relative standard error >0.3 or number of unweighted denominators <50.

Figure 2.2 Trends in the prevalence of current use of any tobacco product^a^ a For 2011–2019, any tobacco product use was defined as use of e-cigarettes, cigarettes, cigars, hookahs, smokeless tobacco, pipe tobacco, and/or bidis (small brown cigarettes wrapped in a leaf) on 1 or more days during the past 30 days. For 2020, any tobacco product use was defined as use of e-cigarettes, cigarettes, cigars, smokeless tobacco, hookahs, pipe tobacco, bidis, or heated tobacco products on 1 or more days during the past 30 days. and any combustible tobacco product^b^ b Any combustible tobacco product use was defined as use of cigarettes, cigars, hookahs, pipe tobacco, and/or bidis (small brown cigarettes wrapped in a leaf) on 1 or more days during the past 30 days. among high school students,^c^ c Data were self-reported by students in grades 9–12. by race and ethnicity; National Youth Tobacco Survey (NYTS) 2011–2020,^d^ d Beginning in 2019, the NYTS was administered as an electronic survey, which included skip patterns and images of tobacco products. Thus, estimates may not be directly comparable to previous years. This change is represented by a break in the trend lines between 2018 and 2019. United States

A Any tobacco product

Among non-Hispanic White, non-Hispanic Black, Hispanic, and all high school students, the prevalence of current use of any tobacco product was lower in 2020 than it was in 2011, even if only slightly so. However, such prevalence was slightly higher in 2020 than it was in 2011 among high school students who identified as non-Hispanic other race. For the 2011-2020 time frame, prevalence of current use of any tobacco product was lowest in 2017 among high school students in each racial and ethnic group.

B Any combustible tobacco product

The prevalence of current use of any combustible tobacco product was lower in 2020 than it was in 2011 for all high school students and high school students in each racial and ethnic group: non-Hispanic White, non-Hispanic Black, Hispanic, and those who identified as non-Hispanic other race. During the 2011-2020 time frame, such prevalence was lowest in 2020 among high school students in all groups, except for high school students who were Hispanic, for which prevalence was the lowest in 2019.

Source: NYTS, CDC, public use data, 2011–2020.

### Patterns of Use of Combustible Tobacco Products

#### Youth

Based on data from the 2020 NYTS, about 9.4% (95% CI, 8.0–11.0) of U.S. high school students reported current use of a combustible tobacco product, defined as having used cigarettes, cigars (cigars, cigarillos, and little cigars), hookahs, pipe tobacco, or bidis on at least 1 day during the past 30 days (Gentzke et al. 2020). Figure 2.2 (Part B) presents trends in the current use of any combustible tobacco product from 2011 to 2020 among U.S. high school students by race and ethnicity. During this period, use of combustible tobacco products had generally declined among all racial and ethnic groups. As noted in Figure 2.2 Part B, beginning in 2019, current use of any combustible tobacco product was higher among Black high school students (16.8%; 95% CI, 14.4–19.5) than it was among high school students of all other races and ethnicities (White: 11.9%; 95% CI, 10.0–14.2; Hispanic: 10.3%; 95% CI, 8.9–11.9; non-Hispanic, Other Race: 7.3%; 95% CI, 4.8–11.0) (Wang et al. 2019). In 2020, current use of any combustible tobacco product remained higher among Black high school students (12.5%; 95% CI, 10.3–15.1) compared with high school students of other races (6.4%; 95% CI, 4.1–9.9); however, Hispanic (10.7%; 95% CI, 8.2–14.0) and White (8.5%; 95% CI, 6.8–10.6) high school students had a similar prevalence of current use of a combustible tobacco product as Black high school students and students of other races.

#### Adults

Data from the NHIS in 2020 revealed differences in use of combustible tobacco products overall by racial and ethnic group. Every-day or some-day use of any combustible tobacco product, including cigarettes, cigars, or pipes (including pipes, water pipes, or hookah), was lower among Asian (8.7%; 95% CI, 7.0–10.7) and Hispanic (9.8%; 95% CI, 8.6–11.0) adults than it was among American Indian and Alaska Native (29.3%; 95% CI, 18.8–41.7), Black (18.0%; 95% CI: 16.2–19.9), and White (16.3%, 95% CI, 15.6–17.0) adults and non-Hispanic adults of other races (21.0%; 95% CI, 16.3–26.4) (Cornelius et al. 2022).

### Patterns of Use of Other Tobacco Products

#### E-Cigarettes

##### Youth

Since 2014, e-cigarettes have been the most commonly used tobacco product among U.S. adolescents (Gentzke et al. 2019). Table 2.3 provides YRBS data from 2019 on the prevalence of ever and current (during the past 30 days) e-cigarette use (known as electronic vapor products in the YRBS) among high school students. For all races and ethnicities assessed, current use of e-cigarettes among adolescents surpassed current use of all other tobacco products—including conventional cigarettes. Current use of e-cigarettes was highest among American Indian and Alaska Native students (47.3%; 95% CI, 34.7–60.4), followed by students who were Native Hawaiian and Other Pacific Islander (38.8%; 95% CI, 28.2–50.5), White (38.3%; 95% CI, 36.0–40.7), multiple race (33.5%; 95% CI, 28.1–39.4), Hispanic (31.2%; 95% CI, 28.6–33.8), Black (19.7%; 95% CI, 16.9–22.8), and Asian (13.0%; 95% CI, 9.5–17.5) (Table 2.3, Part A).

##### Adults

The use of e-cigarettes among adults varied somewhat across racial and ethnic groups. Based on data from the 2020 NHIS, among adults 18 years of age and older, use of e-cigarettes “every day” or “some days” was higher among adults who were of other races (7.8%; 95% CI, 5.1–11.2) than it was among adults who were White (4.2%; 95% CI, 3.8–4.7), Asian (3.4%; 95% CI, 2.3–4.7), Hispanic (2.8%; 95% CI, 2.2–3.5), and Black (1.6%; 95% CI, 1.0–2.3) (Cornelius et al. 2022).

#### Smokeless Tobacco

##### Youth

Based on data from the 2019 YRBS, the prevalence of past-30-day use of smokeless tobacco among youth was higher among American Indian and Alaska Native high school students (16.2%; 95% CI, 7.0–33.2) than it was among White (4.4%; 95% CI, 3.3–5.7), multiple race (3.8%; 95% CI, 2.1–6.8), Hispanic (3.1%; 95% CI, 2.3–4.3), Black (2.8%; 95% CI, 1.8–4.4), and Asian (0.8%; 95% CI, 0.3–1.9) high school students (Table 2.3, Part A). The prevalence of past-30-day smokeless tobacco use also was lower among Asian students than it was among White, multiple race, and Hispanic high school students.

##### Adults

Based on data from the 2019 NSDUH, the prevalence of past-30-day use of smokeless tobacco was higher among (a) adults of multiple races (3.9%; 95% CI, 2.0–5.8), White (4.5%; 95% CI, 4.1–4.8), or American Indian and Alaska Native (7.1%; 95% CI, 3.5–10.6) adults than it was among Black (1.3%; 95% CI, 0.9–1.8) and Hispanic (0.9%; 95% CI, 0.6–1.1) adults; and (b) among White (4.5%; 95% CI, 4.1–4.8) or American Indian and Alaska Native (7.1%; 95% CI, 3.5–10.6) adults than among Asian adults (1.2%; 95% CI, 0.5–2.0) (Table 2.4).

#### Cigars

##### Youth

Based on data from the 2019 YRBS, which treats cigars as a single category that includes large cigars, little/filtered cigars, and cigarillos, the prevalence of past-30-day cigar use was higher among American Indian and Alaska Native high school students (14.9%; 95% CI, 7.4–27.9) than it was among Black (5.3%; 95% CI, 4.1–6.8) and Asian (1.0%; 95% CI, 0.4–3.0) students. The prevalence of past-30-day cigar use was similar among Native Hawaiian and Other Pacific Islander (8.6%; 95% CI, 2.9–22.6), multiple race (6.5%; 95% CI, 4.4–9.6), White (5.9%; 95% CI, 4.7–7.4), Hispanic (6.1%; 95% CI, 4.7–8.0), and Black (5.3%; 95% CI, 4.1–6.8) high school students (Table 2.3, Part A). However, data from the 2020 NYTS show that the prevalence of past-30-day cigar use was higher among Black (9.2%; 95% CI, 7.0–12.1) high school students compared with White (4.2%; 95% CI, 3.2–5.5) high school students (Gentzke et al. 2020).

##### Adults

Data from the 2019 NSDUH show the prevalence of past-30-day cigar use was (a) higher among Black (8.6%; 95% CI, 7.6–9.6) and multiple race (6.9%; 95% CI, 4.6–9.2) adults than it was among Hispanic (3.2%; 95% CI, 2.7–3.8) and Asian (1.4%; 95% CI, 0.8–2.0) adults; and (b) higher among Black adults (8.6%; 95% CI, 7.6–9.6) than it was among American Indian and Alaska Native (4.6%; 95% CI, 2.8–6.4) and White (4.3%; 95% CI, 4.0–4.7) adults (Table 2.4).

#### Pipes, Including Hookahs and Water Pipes

##### Youth

Use of pipe tobacco and hookah or water pipes was not assessed in the 2019 YRBS. However, the NYTS assesses use of pipe tobacco and hookah or water pipes. Data from the 2020 NYTS show that past-30-day hookah use was higher among Hispanic (4.45%; 95% CI, 2.8–6.9) and Black (3.9%; 95% CI, 2.5–6.0) high school students than it was among White high school students (1.8%; 95% CI, 1.3–2.3) (Gentzke et al. 2020). The prevalence of past-30-day use of pipe tobacco was low among high school students overall (0.7%; 95% CI, 0.5–1.1), making it difficult to obtain stable estimates of pipe tobacco use for all races and ethnicities (Gentzke et al. 2020).

##### Adults

Data from the 2019 NSDUH show the prevalence of past-30-day pipe use was higher among multiple race adults (3.1%; 95% CI, 1.7–4.6) than it was among Black (0.7%; 95% CI, 0.4–1.0), Hispanic (0.5%; 95% CI, 0.3–0.7), and White (0.8%; 95% CI, 0.6–1.0) adults (Table 2.4).

According to the 2019 NHIS, about 1% of adults, overall, report current use (every day or some days) of regular pipes, hookah, or waterpipes (Cornelius et al. 2020). By race and ethnicity, current use of pipes, hookah, or waterpipes did not differ between White (1.0%; 95% CI, 0.8–1.2), Black (1.1%; 95% CI, 0.7–1.5), and Hispanic (0.8%; 95% CI, 0.5–1.1) adults; estimates were unstable and not reported among Asian adults, American Indian and Alaska Native adults, and non-Hispanic adults of other races.

### Patterns of Use of Emerging Tobacco Products

The availability of tobacco products continues to evolve as emerging and modified tobacco products are introduced into the U.S. marketplace. For example, various heated tobacco products were unsuccessfully market-tested in the United States in the late 1980s (Simonavicius et al. 2019). Currently, the only heated tobacco product authorized for sale in the United States is IQOS (Philip Morris Products S.A.), which gained such authorization in April 2019 through FDA’s Premarket Tobacco Product Application (PMTA) pathway (FDA 2019). Sales were stopped in November 2021 due to a patent lawsuit (United States International Trade Commission 2022). Nicotine pouches entered the U.S. market in 2016. These prefilled, microfiber pouches contain nicotine powder that dissolves in the mouth without spitting (Marynak et al. 2021).

#### Youth

According to data from the 2021 NYTS, 1.8% (95% CI, 1.5–2.0) of U.S. middle and high school students reported ever using heated tobacco products; this finding was similar across racial and ethnic groups (Gentzke et al. 2022).

Overall, 1.9% (95% CI, 1.5–2.4) of U.S. middle and high school students in 2021 reported they had ever used nicotine pouches. Reported ever use of nicotine pouches was higher among White students (2.6%; 95% CI, 2.1–3.3) than it was among students who were Hispanic (1.3%; 95% CI, 0.9–1.3) or Black (0.7%; 95% CI, 0.4–1.3). Current (during the past 30 days) use of heated tobacco products and nicotine pouches was low among middle and high school students (0.7%; 95% CI, 0.5–0.8 and 0.8; 95% CI, 0.6–1.0, respectively), making it difficult to obtain stable estimates of such use among middle and high school students of all races and ethnicities (Gentzke et al. 2022).

#### Adults

According to data from the 2019 TUS-CPS, 8.6% (95% CI, 8.3–8.9) of adults were aware of heated tobacco products, among whom 5.8% (95% CI, 4.9-6.6) reported having ever used these products (Azagba and Shan 2021). However, the prevalence of ever use of heated tobacco products among all adults was low (0.5%; 95% CI, 0.4–0.6). No statistically significant differences in awareness or use of heated tobacco products were observed by race and ethnicity.

Nationally representative data on nicotine pouch use among adults are unavailable.

### Patterns of Polytobacco Use

Attention to dual use and polyuse of tobacco products is gaining momentum, but relatively few studies are available that assess differences in dual use and polyuse across racial and ethnic populations.

#### Youth

Among high school students in the 2019 YRBS, polytobacco use was defined as having used two or more tobacco products during the past 30 days. Polytobacco use was higher among American Indian and Alaska Native students (23.8%; 95% CI, 13.4–38.5) than it was among White students (9.5%; 95% CI, 7.8–11.5). Polytobacco use was also higher among Native Hawaiian and Other Pacific Islander (15.7%; 95% CI, 6.4–12.7), White (9.5%; 95% CI, 7.8–11.5), and multiple race (9.2%; 95% CI, 6.6–12.7) students than it was among Black (4.8%; 95% CI, 3.7–6.2) and Asian (2.5%; 95% CI, 1.3–4.8) students; and was higher among Hispanic students (7.9%; 95% CI, 6.2–10.0) than it was among Asian students (2.5%; 95% CI, 1.3–4.8) (Table 2.3, Part A).

#### Adults

According to data from the 2019 NSDUH, the prevalence of polytobacco use (defined as having used two or more of the following tobacco products during the past month: cigarettes, cigars, smokeless tobacco, or pipes) was higher among multiple race (7.7%; 95% CI, 5.1–10.3), American Indian and Alaska Native, (6.6%; 95% CI, 4.3–9.0), and Black (4.8%; 95% CI, 4.0–5.6) adults than it was among White (3.6%; 95% CI, 3.3–3.9), Hispanic (2.2%; 95% CI, 1.8–2.6) and Asian adults (0.6%; 95% CI, 0.3–0.9) (Table 2.4).

E-cigarettes were not assessed in the 2019 NSDUH and are not included in the estimate of polytobacco use presented in Table 2.4. However, estimates of polytobacco use including e-cigarettes can be obtained from other sources. For example, the NHIS defines polytobacco use as having used two or more of the following tobacco products “every day” or “some days”: cigarettes; cigars; pipes, water pipes, or hookah; smokeless tobacco; or e-cigarettes. In the 2019 NHIS, the prevalence of polytobacco use was higher among non-Hispanic adults of other races (7.5%; 95% CI, 4.7–10.3) than it was among Black (3.3%; 95% CI, 2.5–4.1), Hispanic (2.2%; 95% CI, 1.7–2.7), and Asian (1.4%; 95% CI, 0.8–2.0) adults (Cornelius et al. 2020). Additionally, the prevalence of polytobacco use was higher among White adults (4.5%; 95% CI, 4.1–4.9) than it was among Hispanic (2.2%; 95% CI, 1.7–2.7) and Asian (1.4%; 95% CI, 0.8–2.0) adults. The prevalence of polytobacco use from the 2019 NHIS was not available for American Indian and Alaska Native adults (Cornelius et al. 2020).

### Patterns of Co-Use with Other Substances

Among adolescents and adults, the co-occurring use of tobacco with alcohol and other substances has been reported across racial and ethnic groups (Falk et al. 2006; Johnson et al. 2009; Luczak et al. 2017). The extent of this co-occurrence differs materially by racial and ethnic groups. For example, Falk and colleagues (2006) found that co-use of tobacco and alcohol was highest among American Indian men (34.0%) and lowest among Asian, Native Hawaiian, and Pacific Islander women (6.6%).

The intersection between race and ethnicity and polysubstance use has received a lot of attention, particularly in the case of tobacco and marijuana use (hereafter described as “cannabis use”) among Black adults compared with White and Hispanic adults (Ramo et al. 2012; Schauer et al. 2015, 2017; Montgomery and Oluwoye 2016; Montgomery and Mantey 2017; Montgomery and Ramo 2017; Trapl et al. 2018; Montgomery et al. 2020; Mantey et al. 2021). Although tobacco and cannabis co-use (assessed as using both products during the past month) increased from 2003 to 2012 among adults overall, there was a faster increase among Black and Hispanic adults compared with White adults (Schauer et al. 2015).

Many studies have also assessed tobacco and cannabis co-use as blunt use—in which cannabis is wrapped inside the shell of a cigar or cigarillo. An analysis of the 2014 NSDUH found that an estimated 8.3% of Black, 3.3% of Hispanic, and 2.5% of White adults currently (during the past 30 days) used blunts (Montgomery and Mantey 2017, 2018). Additionally, in the NSDUH study, the prevalence of current blunt use was 5.3% among Black, 4.3% among Hispanic, and 3.8% among White adolescents (Montgomery and Mantey 2018). Some evidence indicates that people who use blunts may not consider themselves to use cigars or cigarillos, which may result in underestimates of the use of cigars and cigarillos (Yerger et al. 2001; Delnevo et al. 2011a).

### Patterns of Tobacco Use During the Life Course

A growing body of research indicates the importance of examining racial and ethnic differences in tobacco use during the life course to complement the findings available for various age categories of interest, such as adolescence or late adulthood. Such research has uncovered different patterns of smoking across the age continuum.

Among adolescents, understanding the patterns of racial and ethnic differences in tobacco use is made more complex by racial and ethnic differences in average age of tobacco initiation (Caraballo et al. 2006; Lawrence et al. 2014) and differences in the products that are most commonly tried first (Ross et al. 2018). For example, compared with White people, many Asian and Black people start smoking cigarettes at older ages (Trinidad et al. 2004; Chen and Jacobson 2012; Roberts et al. 2016a; NCI 2017), and Hispanic people are more likely than people in other racial and ethnic groups to try cigarettes as their first tobacco product (Ross et al. 2018). Although the prevalence of tobacco product use was generally lower among Black and Asian groups than other racial and ethnic groups during early adolescence, an older study that joined data from the 1992–1993, 1995–1996, and 1998–1999 TUS-CPS found that Black and Asian people were the most likely groups to begin tobacco product use during adulthood (Trinidad et al. 2004).

Data on trends from 2006 to 2013 support increases in the onset of cigarette smoking (moving from never having smoked to having smoked cigarettes every day for at least 30 days during the past 12 months) among Black and Hispanic young men with slower declines in smoking onset among Black and Hispanic young women compared with their respective White counterparts (Thompson et al. 2018). Regarding rates of cessation, three studies found that they were higher for White adults compared with Black adults (Pampel 2008; Kandel et al. 2011; Trinidad et al. 2011). Although the prevalence of smoking declines with advancing age for all racial and ethnic groups, the prevalence of cigarette use among adults 65 years of age and older is higher among Black people than it is among White people (Table 2.5).

This pattern, in which the prevalence of smoking among Black people is lower than that of White people during adolescence but later equals or exceeds that of White people during adulthood, is known as crossover or convergence (Arnett and Brody 2008; Pampel 2008; Keyes et al. 2015; Giovino and Gardiner 2016). Two earlier studies assessing the crossover effect between non-Hispanic Black and non-Hispanic White people found evidence that the age crossover effect occurred by age 30 (Geronimus et al. 1993; Kandel et al. 2011). The findings align with other research examining lifetime smoking, which indicates that American Indian people have the longest median duration of smoking (32 years), followed by Black and “Other” race (30 years), White (28 years), and Hispanic people (24 years) (Siahpush et al. 2010). Some evidence indicates that the racial crossover may be more pronounced in women than men (Caraballo et al. 2016).

According to data from the Monitoring the Future Study, in the late 1970s, the prevalence of smoking among adolescents and young adults of different racial and ethnic groups was similar (Nelson et al. 2008; Oredein and Foulds 2011). However, between the late 1970s and early 1990s, the prevalence of cigarette smoking declined significantly among Black and Hispanic adolescents and young adults, leading to a substantial gap in the prevalence of smoking, especially between Black and White adolescents (Nelson et al. 2008). By the early 1990s, smoking was two to four times higher among Hispanic and White adolescents compared with Black adolescents. Since 1991, trends in cigarette smoking among adolescents have been similar across racial and ethnic groups, although the prevalence remained lower among Black adolescents. Additionally, since about 1990, overall trends in cigarette smoking among young adults were similar to trends among adolescents but lagged by a couple of years. This pattern suggests a cohort effect, with previous adolescent smoking behavior affecting subsequent smoking behavior among young adults (Nelson et al. 2008). Further research on this topic is needed, using cross-sectional and prospective studies, as well as studies of age cohorts to document differences in behavior over calendar time.

### Patterns of Tobacco Use by Race and Ethnicity and Sex

Among adults, NSDUH data from 2019 (Table 2.7) show differences in the prevalence of tobacco product use by sex within racial and ethnic groups. The prevalence of ever cigarette use was higher among Asian (47.8%; 95% CI, 43.0–52.6 vs. 18.9%; 95% CI, 14.5–23.3), Black (49.9%; 95% CI, 46.8–53.0 vs. 41.3%; 95% CI, 38.5–44.0), Hispanic (55.0%; 95% CI, 52.7–57.4 vs. 37.8%; 95% CI, 35.3–40.2), and White (71.1%; 95% CI, 70.1–72.2 vs. 65.2%; 95% CI, 63.7–66.7) men than it was among women. Similarly, the prevalence of past-month cigarette use was higher among Asian (12.0%; 95% CI, 9.3–14.7 vs. 4.6%; 95% CI, 3.0–6.2), Black (24.7%; 95% CI, 22.1–27.3 vs. 17.1%; 95% CI, 15.2–19.0) and Hispanic (17.6%; 95% CI, 15.8–19.5 vs. 9.3%; 95% CI, 7.8–10.8) men than it was among women.

The prevalence of past-month cigar use was higher among men than it was among women who were Black (male: 12.4%; 95% CI, 10.7–14.0 vs. female: 5.4%; 95% CI, 4.5–6.4), Hispanic (5.2%; 95% CI, 4.1–6.3 vs. 1.3%; 95% CI, 0.9–1.7), or White (7.2%; 95% CI, 6.6–7.8 vs. 1.6%; 95% CI, 1.3–1.9). The prevalence of past-month smokeless tobacco product use was higher among men than it was among women who were Black (2.1%; 95% CI, 1.2–3.0 vs. 0.7%; 95% CI, 0.3–1.1) or White (8.5%; 95% CI, 7.8–9.2 vs. 0.7%; 95% CI, 0.5–0.8). The prevalence of past-month pipe use was higher among White men (1.3%; 95% CI, 1.0–1.6) than it was among White women (0.3%; 95% CI, 0.2–0.5). The prevalence of the use of two or more tobacco products during the past month was higher among men than it was among women who were Black (7.5%; 95% CI, 6.1–9.0 vs. 2.6%; 95% CI, 2.0–3.1), Hispanic (3.4%; 95% CI, 2.7–4.2 vs. 1.0%; 95% CI, 0.6–1.4), or White (5.8%; 95% CI, 5.2–6.4 vs. 1.4%; 95% CI, 1.2–1.7).

Among high school students, data from the 2019 YRBS indicate that current use of cigars (8.1%; 95% CI, 6.6–10.0 vs. 3.5%; 95% CI, 2.3–5.2), smokeless tobacco (7.6%; 95% CI, 5.7–10.0 vs. 0.9%; 95% CI, 0.6–1.5), and use of two or more tobacco products (12.3%; 95% CI, 10.4–14.4 vs. 6.6%; 95% CI, 4.6–9.4) was higher among White adolescent males than it was among White adolescent females. No other differences in use of other tobacco products were observed by sex among other racial and ethnic groups (Table 2.3, Part B).

### Variation Within Aggregate Racial and Ethnic Groups

Within aggregate racial and ethnic groups, the prevalence of tobacco use often varies by population. This variation may not be captured in national surveillance studies. For example, although the prevalence of current cigarette use is relatively low among Asian people who speak English in the United States when reported in aggregate, prevalence varies considerably by sex and country of ancestry within this population (Chae et al. 2006; Mukherjea et al. 2014). One analysis of national data found that current cigarette use was highest among Korean (26.6%; 95% CI, 21.3–32.7), Vietnamese (21.5%; 95% CI, 16.4–27.7), and Filipino (16.7%; 95% CI, 13.7–20.2) adults and lowest among Japanese (12.1%; 95% CI, 9.2–15.8), Asian Indian (11.8%; 95% CI 8.9–15.4), and Chinese adults (8.8%; 95% CI, 6.9–11.3) (Martell et al. 2016). In another study (Mukherjea et al. 2014) of Asian American and Native Hawaiian and Pacific Islander adults, current cigarette smoking was highest among Native Hawaiian and Pacific Islander adults (20%), and preference for menthol-flavored cigarettes was highest among Filipino (45%) and Native Hawaiian and Pacific Islander (46%) adults who smoked cigarettes.

Further, although the prevalence of tobacco use is relatively high among American Indian and Alaska Native people (Odani et al. 2017), prevalence varies widely across the country (Nez Henderson et al. 2005; Eichner et al. 2010; Redwood et al. 2010). For example, one study found that current cigarette use was much higher among American Indian and Alaska Native people in Alaska (31.6%) than among those in the Southwest (8.3%) (Redwood et al. 2010).

Research also indicates substantial variation within the Hispanic population (Kaplan et al. 2014; Dominguez et al. 2015). For example, a study by Martell and colleagues (2016) found that the prevalence of current cigarette smoking during 2010–2013 was highest among Puerto Rican adults (28.5%; 95% CI, 25.8–31.4), followed by Cuban (19.8%; 95% CI, 16.5–23.6), Mexican (19.1%; 95% CI, 18.2–20.1), and Central or South American adults (15.6%; 95% CI, 13.5–18.0).

However, knowledge of differences within racial and ethnic populations is limited to the groups assessed. Thus, additional disparities may emerge with changes to U.S. Census measures and other classifications (U.S. Census Bureau 2021). For example, Arab American people and other people from the Middle East are currently classified as “White” (Kayyali 2013), which may mask differences in the use of tobacco products as they relate to country of ancestry and common products used in the Arabian Gulf region (Maziak et al. 2015; Vupputuri et al. 2016). Data collected during 2004–2005 suggest that hookah use was higher among Arab American youth than among non-Arab American youth (Weglicki et al. 2008). Arab American men also have a higher prevalence of ever and current cigarette smoking than White men; however, the prevalence of ever and current smoking is lower among Arab American women than it is among White women (Abuelezam et al. 2021).

### Nativity and Acculturation

In 2019, more than 44.9 million people in the United States were foreign born; this equated to 13.7% of the total U.S. population (U.S. Census Bureau n.d.c). Although immigrants to the United States come from all over the world, estimates indicate that most foreignborn people in the United States come from Latin America (50.3%), Asia (31.4%), and Europe (10.4%) (U.S. Census Bureau n.d.c). In terms of specific countries, the largest proportions of foreign-born people in the United States originated from Mexico (25%), India (6%), China (6%, excluding Hong Kong and Taiwan), and the Philippines (4%) (Budiman 2020).

Immigrants enter the United States with their own cultural backgrounds regarding tobacco use. According to a review performed by NCI (2017), a small but growing body of research demonstrates how these backgrounds—as well as the processes of acculturation in and assimilation to the United States—create a complex network of factors that influence tobacco use outcomes for youth and adults. Data from the TUS-CPS found that participants who took the survey in a language other than English (a proxy for English language proficiency) and earlier immigrant generation status (first and second generation compared with third generation) were associated with higher prevalence of a past-year quit attempt among Hispanic adults (Gundersen et al. 2012). Whether acculturation is a risk or a protective factor for tobacco use may depend on the interplay of ethnicity, sex, and SES (Zhu et al. 2007; Tong et al. 2012; NCI 2017).

Pooled data from the 2019–2021 NHIS found that the prevalence of ever cigarette use, current cigarette use (defined as having smoked at least 100 cigarettes in one’s lifetime and smoking cigarettes every day or some days), and current use of cigars, smokeless tobacco, e-cigarettes, and multiple tobacco products (defined as having used such products every day or some days) was lower among foreign-born people than among their U.S.-born counterparts (Table 2.8). Of note, pooling data for foreignborn people of various races and ethnicities may mask differences in tobacco product use behaviors by country of origin. For example, although aggregate Hispanic or Latino and Asian populations have a lower-than-average prevalence of smoking overall (Figure 2.1), both groups represent diverse populations and variations in the patterns of tobacco use have been observed by country of origin (Blanco et al. 2014; Gorman et al. 2014) (also see Chapter 6).

Current cigarette use overall was nearly two times higher among U.S.-born people (13.8%; 95% CI, 13.5–14.2) than it was among foreign-born people (7.4%; 95% CI, 6.9–8.0) and this pattern was consistent for use of cigars (3.9%; 95% CI, 3.8–4.1 vs. 1.7%; 95% CI, 1.4–1.9), smokeless tobacco (2.7%; 95% CI, 2.6–2.9 vs. 0.3%; 95% CI, 0.2–0.4), e-cigarettes (4.8%; 95% CI, 4.6–5.0 vs. 1.6%; 95% CI, 1.4–1.9), and multiple tobacco products (4.0%; 95% CI, 3.8–4.2 vs. 1.5%; 95% CI, 1.3–1.8) (Table 2.8). Smoking cessation outcomes, in contrast, were comparable between foreign- and U.S.-born people.

Pooled NHIS data from 2019 to 2021 reveal that the prevalence of ever using cigarettes was higher among men than it was among women for each of the nativity groups (Table 2.9). The disparity by sex was wider among foreign-born people. Among U.S.-born people, men and women were separated by an absolute difference of 8 percentage points in prevalence of ever using cigarettes (men: 42.4%; 95% CI, 41.7–43.1 vs. women: 34.4%; 95% CI, 33.6–34.9), but among foreign-born people, the difference in the prevalence of ever use was 20.4 percentage points (men: 33.8%; 95% CI, 32.3–35.2 vs. women: 13.4%; 95% CI, 12.6–14.3). When examining current use of tobacco in its various forms by sex, foreign-born women reported the lowest prevalence of using all products compared with foreign-born men, U.S.-born women, and U.S.-born men (Table 2.9).

When examining differences in tobacco use by nativity and age, ever use of cigarettes and current use of smokeless tobacco products and e-cigarettes were consistently and significantly lower among foreign-born people than among U.S.-born people across all specific age groups: 18–24 years of age, 25–44 years of age, 45–64 years of age, and 65 years of age and older (Table 2.9). For other tobacco products, use was consistently, though not always statistically, lower among foreign-born adults than it was among U.S.-born adults across all age groups.

Table 2.8 Prevalence of ever use of cigarettes, current use of tobacco products, and smoking cessation among adults, 18 years of age and older, by nativity and sex; National Health Interview Survey (NHIS) 2019–2021, United States

Nativity | Ever use of cigarettes:^b^ % (95% CI) | Current use of tobacco products:^a^ % (95% CI) | | | | | | Smoking cessation: % (95% CI)
Nativity | Ever use of cigarettes:^b^ % (95% CI) | Cigarettes | Cigars | Smokeless tobacco | Pipes^c^ | E-cigarettes | ≥2 tobacco products^d^ | Attempt in past year^e^ | Quit for ≥6 month^f^
U.S. born | 38.2 (37.7–38.7) | 13.8 (13.5–14.2) | 3.9 (3.8–4.1) | 2.7 (2.6–2.9) | 1.1 (0.9–1.2) | 4.8 (4.6–5.0) | 4.0 (3.8–4.2) | 54.9 (52.6–57.1) | 8.4 (7.2–9.6)
Female | 34.3 (33.6–34.9) | 13.0 (12.5–13.4) | 1.1 (1.0–1.2) | 0.3 (0.2–0.4) | 0.7 (0.5–0.8) | 4.0 (3.8–4.3) | 2.2 (2.0–2.4) | 54.8 (51.7–57.8) | 8.1 (6.4–9.9)
Male | 42.4 (41.7–43.1) | 14.7 (14.2–15.2) | 7.0 (6.6–7.3) | 5.3 (5.0–5.6) | 1.5 (1.3–1.6) | 5.6 (5.3–6.0) | 5.8 (5.5–6.1) | 55.0 (51.9–58.1) | 8.6 (7.0–10.3)
Foreign born | 23.1 (22.3–23.9) | 7.4 (6.9–8.0) | 1.7 (1.4–1.9) | 0.3 (0.2–0.4) | 0.8 (0.6–1.0) | 1.6 (1.4–1.9) | 1.5 (1.3–1.8) | 59.7 (53.6–65.7) | 6.1 (3.4–8.7)
Female | 13.4 (12.5–14.3) | 3.9 (3.4–4.4) | 0.4 (0.2–0.6) | —^g^ (0.3–0.6) | 0.5 (0.6–1.0) | 0.8 (0.4–0.8) | 0.6 (49.9–69.8) | 59.9 (2.1–13.1) | 7.6
Male | 33.8 (32.3–35.2) | 11.4 (10.4–12.4) | 3.0 (2.5–3.6) | 0.6 (0.4–0.8) | 1.1 (0.8–1.4) | 2.5 (2.1–3.0) | 2.5 (2.1–3.0) | 59.6 (52.3–66.8) | 5.4 (2.4–8.4)

Source: NHIS, National Center for Health Statistics, public use data, 2019–2021; ever use of cigarettes and current use of tobacco are based on 2019–2021 data; and smoking cessation outcomes are based on 2020 data.

Notes: CI = confidence interval.

a People who currently smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes and smoking cigarettes every day or some days at the time of the survey. People who currently used other products (cigars, smokeless tobacco, pipe, e-cigarettes) was defined as those who reported having used such products every day or some days.

b People who had ever smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes.

c Pipes included the use of regular pipes, water pipes, or hookah.

d Any combination of more than one tobacco product.

e Attempt in past year was defined as the percentage of people who (a) currently smoked cigarettes and reported having stopped smoking for more than 1 day during the past 12 months because they were trying to quit smoking and (b) quit smoking during the past year.

f Quit for at least 6 months was defined as the percentage of people who used to smoke cigarettes and reported having quit smoking for at least 6 months during the past year, among people who currently smoked cigarettes for at least 2 years and people who had quit smoking during the past year.

g Unstable estimate is not presented because of a relative standard error >0.3 or number of unweighted denominators <50.

Table 2.9 Prevalence of ever use of cigarettes and current use of tobacco products among adults, 18 years of age and older, by nativity, sex, and age group; National Health Interview Survey (NHIS) 2019–2021, United States

Nativity, sex and age group | Ever use of cigarettes:^b^ % (95% CI) | Current use of tobacco products:^a^ % (95% CI)
Nativity, sex and age group | Ever use of cigarettes:^b^ % (95% CI) | Cigarettes | Cigars | Smokeless tobacco | Pipes^c^ | E-cigarettes | ≥2 tobacco products^d^
By sex
U.S. born
Male | 42.4 (41.7–43.1) | 14.7 (14.2–15.2) | 7.0 (6.6–7.3) | 5.3 (5.0–5.6) | 1.5 (1.3–1.7) | 5.6 (5.3–6.0) | 5.8 (5.5–6.2)
Female | 34.3 (33.6–34.9) | 13.0 (12.5–13.4) | 1.1 (1.0–1.2) | 0.3 (0.2–0.4) | 0.7 (0.5–0.8) | 4.0 (3.8–4.3) | 2.2 (2.0–2.4)
Foreign born
Male | 33.8 (32.3–35.2) | 11.4 (10.4–12.4) | 3.0 (2.6–3.6) | 0.6 (0.4–0.8) | 1.1 (0.8–1.5) | 2.5 (2.1–3.1) | 2.5 (2.1–3.0)
Female | 13.4 (12.6–14.3) | 3.9 (3.4–4.4) | 0.4 (0.3–0.7) | —^e^ | 0.5 (0.3–0.7) | 0.8 (0.6–1.1) | 0.6 (0.4–0.8)
By age group
U.S. born
18–24 | 12.7 (11.7–13.9) | 7.2 (6.4–8.1) | 3.8 (3.2–4.5) | 2.2 (1.8–2.8) | 1.8 (1.4–2.2) | 10.2 (9.3–11.3) | 5.2 (4.5–6.0)
25–44 | 35.4 (34.6–36.2) | 16.1 (15.5–16.8) | 5.4 (5.1–5.8) | 3.5 (3.2–3.8) | 1.6 (1.4–1.8) | 7.1 (6.6–7.5) | 6.0 (5.6–6.4)
45–64 | 43.8 (42.9–44.6) | 17.6 (17.0–18.2) | 3.9 (3.6–4.2) | 3.2 (3.0–3.5) | 0.6 (0.5–0.7) | 3.1 (2.9–3.4) | 3.3 (3.1–3.6)
≥65 | 49.0 (48.2–49.8) | 8.9 (8.5–9.4) | 2.0 (1.8–2.2) | 1.3 (1.1–1.5) | 0.4 (0.4–0.5) | 0.9 (0.7–1.0) | 1.2 (1.0–1.4)
Foreign born
18–24 | 7.6 (5.6–10.3) | 4.6 (3.1–6.8) | 2.7 (1.6–4.7) | —^e^ | —^e^ | 6.0 (4.2–8.6) | 3.7 (2.4–5.6)
25–44 | 19.9 (18.7–21.3) | 8.1 (7.2–9.0) | 2.3 (1.8–2.9) | 0.5 (0.3–0.8) | 1.3 (1.0–1.7) | 2.2 (1.8–2.7) | 2.1 (1.7–2.6)
45–64 | 25.4 (24.0–26.9) | 8.1 (7.3–9.1) | 1.3 (1.0–1.7) | —^e^ | 0.3 (0.2–0.5) | 0.8 (0.6–1.2) | 1.0 (0.8–1.4)
≥65 | 31.7 (29.7–33.8) | 5.7 (4.7–6.9) | 0.8 (0.5–1.2) | —^e^ | —^e^ | —^e^ | 0.5 (0.3–0.9)

Source: NHIS, National Center for Health Statistics, public use data, 2019–2021.

Notes:CI = confidence interval; N/A = not available.

a People who currently smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes and smoking cigarettes every day or some days at the time of the survey. People who currently used other products (cigars, smokeless tobacco, pipe, e-cigarettes) was defined as those who reported having used such products every day or some days at the time of the survey.

b People who had ever smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes.

c Pipes included the use of regular pipes, water pipes, or hookah.

d Any combination of more than one tobacco product.

e Unstable estimate is not presented because of a relative standard error >0.3 or number of unweighted denominators <50.

## Tobacco Use by Sexual Orientation and Gender Identity

### Patterns of Ever and Current Use of Cigarettes

Disparities in tobacco use by sexual orientation and gender identity are evident; however, data are limited because of the lack of standard measurements across data collection instruments and surveillance systems. Recommendations from scientific organizations—including USDHHS; the National Institutes of Health; and the National Academies of Science, Engineering, and Medicine—have encouraged defining and measuring sexual orientation and gender identity across studies to fill this evidence gap (Dermody et al. 2020; National Academies of Sciences, Engineering, and Medicine 2022; National Institutes of Health n.d.; USDHHS n.d.).

This section focuses on patterns of tobacco use by sexual orientation. Among adults, combined data from the 2019 to 2021 NHIS are presented to report the prevalence of tobacco use behaviors among (a) heterosexual adults compared with adults who identify with a minoritized sexual orientation group (includes responses from those who reported identifying as “gay,” “lesbian,” or “bisexual” or who reported “something else” as their sexual orientation) and (b) gay, lesbian, or bisexual adults compared with heterosexual adults. Among youth, patterns of tobacco use by sexual orientation (heterosexual compared to gay, lesbian, or bisexual) are presented from the 2019 YRBS.

The NHIS and the YRBS did not collect data on gender identity during these years, which reflects a limited amount of research in the gender identity research domain. However, the NHIS and YRBS began assessing gender identity in 2022 and 2023, respectively.^1^ Disparities in tobacco use by gender identity have been assessed using other surveys of adults (Buchting et al. 2017; Wheldon and Wiseman 2019) and youth, including recent administrations of the NYTS (Gentzke et al. 2022).

#### Youth

In 2019, the YRBS estimated that 22.7% (95% CI, 19.9–25.8) of heterosexual high school students had ever tried a cigarette compared with 32.9% (95% CI, 28.1–38.0) of gay, lesbian, or bisexual high school students (Table 2.10). The prevalence of ever cigarette use among students who were unsure about their sexual orientation (19.9%; 95% CI, 15.2–25.6) was lower compared with gay, lesbian, or bisexual high school students. As a group, gay, lesbian, and bisexual high school students had the highest prevalence of past-30-day use of cigarettes (10.4%; 95% CI, 7.8–13.7) compared with 5.2% (95% CI, 4.3–6.3) of heterosexual students (Table 2.10). Based on data from the 2019 YRBS, an estimated 6.9% (95% CI, 5.8–8.2) of heterosexual high school students first used a cigarette before 13 years of age; estimates of such use were higher for gay, lesbian, and bisexual students combined (12.1%; 95% CI, 9.9–14.7) and specifically for gay, lesbian, and bisexual students who were female (12.3%; 95% CI, 9.5–15.7) compared with heterosexual students who were female (5.5%; 95% CI, 4.5–6.6) (CDC n.d.h).

#### Adults

Combined data from the NHIS from 2019 to 2021 reveal that ever use of cigarettes by adults was higher among adults who identified with a minoritized sexual orientation group (including individuals who identified as gay, lesbian, bisexual, or who reported “something else”) (38.0%; 95% CI, 36.0–40.0) than it was among heterosexual adults (35.4%; 95% CI, 34.9–35.9) (Table 2.11). Similarly, current use of cigarettes was greater among adults who identified with a minoritized sexual orientation group (16.3%; 95% CI, 14.8–17.9)—specifically, bisexual (18.0%; 95% CI, 15.7–20.6) and gay (16.3%; 95% CI, 13.2–19.9) adults—than it was among adults who identified as heterosexual (12.5%, 95% CI, 12.2–12.8) (Table 2.11). Among young adults (18–24 years of age), the prevalence of ever and current cigarette use was higher among bisexual people (22.2%; 95% CI, 17.5–27.7, and 11.9%; 95% CI, 8.5–16.3, respectively) compared with heterosexual people (11.6%; 95% CI, 10.6–12.7 and 6.6%; 95% CI, 5.8–7.4, respectively) (Table 2.11).

### Patterns of Frequency and Quantity of Cigarette Use

#### Youth

According to the 2019 YRBS, the prevalence of frequent cigarette use (use on 20 or more days during the past 30 days) was higher among gay and lesbian high school students (4.2%; 95% CI, 1.6–10.4) than it was among heterosexual students (1.1%; 95% CI, 0.8–1.5); frequent cigarette use was comparable among bisexual students (2.1%; 95% CI, 1.1–4.2), students who were unsure of their sexual orientation (2.5%; 95% CI, 1.0–6.2), and heterosexual students (1.1%; 95% CI, 0.8–1.5) (CDC n.d.c). Regarding daily cigarette use, 0.9% (95% CI, 0.7–1.3) of heterosexual students; 4.1% (95% CI, 1.5–10.3) of gay or lesbian students; 1.4% (95% CI, 0.6–3.0) of bisexual students; and 2.4% (95% CI, 0.9–6.2) of students who were unsure of their sexual orientation smoked cigarettes daily (i.e., every day during the previous 30 days) (CDC n.d.b).

Table 2.10 Prevalence of ever use of cigarettes and electronic vapor products, current use of tobacco products, and ever making an attempt to quit all tobacco products among high school students by sexual orientation; national Youth Risk Behavior Survey (YRBS) 2019, United States

Sexual orientation | Ever use of cigarettes:^b^ % (95% CI) | Ever use of electronic vapor products:^c^ % (95% CI) | Current use of tobacco products:^a^ % (95% CI)
Sexual orientation | Ever use of cigarettes:^b^ % (95% CI) | Ever use of electronic vapor products:^c^ % (95% CI) | Cigarettes | Cigars^d^ | Smokeless tobacco^e^ | Electronic vapor products^f^ | ≥2 tobacco products^g^ | Ever quit attempt:^h^ % (95% CI)
Heterosexual | 22.7 (19.9–25.8) | 49.8 (47.7–52.0) | 5.2 (4.3–6.3) | 5.2 (4.4–6.1) | 3.7 (3.1–4.4) | 32.8 (30.5–35.2) | 7.8 (6.7–9.0) | 47.4 (44.6–50.2)
Gay, lesbian, or bisexual | 32.9 (28.1–38.0) | 56.0 (52.2–59.7) | 10.4 (7.8–13.7) | 8.1 (5.9–11.1) | 3.2 (2.0–5.2) | 34.1 (30.8–37.6) | 10.4 (8.0–13.5) | 50.8 (42.5–59.0)
Not sure | 19.9 (15.2–25.6) | 37.2 (30.9–43.9) | 7.4 (4.8–11.3) | 7.2 (4.3–12.0) | 5.5 (3.1–9.4) | 24.9 (19.8–30.7) | 8.1 (5.4–11.9) | 40.5 (25.5–57.5)

Source: CDC (n.d.a).

Notes:CI = confidence interval.

a On at least 1 day during the 30 days before the survey.

b Even one or two puffs.

c Even one or two puffs; includes use of e-cigarettes, vapes, vape pens, e-cigars, e-hookahs, hookah pens, and mods (e.g., JUUL, Vuse, MarkTen, and blu).

d Includes use of cigars, cigarillos, or little cigars on at least 1 day during the 30 days before the survey.

e Includes use of chewing tobacco, snuff, dip, snus, or dissolvable tobacco products—such as Redman, Levi Garrett, Beechnut, Skoal, Skoal Bandits, Copenhagen, Camel Snus, Marlboro Snus, General Snus, Ariva, Stonewall, or Camel Orbs—not counting any electronic vapor products, on at least 1 day during the 30 days before the survey,

f Includes use of e-cigarettes, vapes, vape pens, e-cigars, e-hookahs, hookah pens, and mods (e.g., JUUL, Vuse, MarkTen, and blu) on at least 1 day during the 30 days before the survey.

g Percentage of students who used two or more of the following tobacco products: cigarettes, cigars (cigars, cigarillos, or little cigars), an electronic vapor product, or smokeless tobacco, on 1 or more days during the 30 days before the survey.

h Includes ever quit attempt of cigarettes, cigars, smokeless tobacco, shisha or hookah tobacco, and electronic vapor products during the 12 months before the survey, among high school students who used any tobacco products during the 12 months before the survey.

Table 2.11 Prevalence of ever use of cigarettes, current use of tobacco products, and smoking cessation among adults (≥18 years of age and older) and young adults (18–24 years of age), by sexual orientation; National Health Interview Survey (NHIS) 2019–2021 combined data, United States

Age group and sexual orientation | Ever use of cigarettes:^b^ % (95% CI) | Current use of tobacco products:^a^ % (95% CI) | | | | | | Smoking cessation (2020): % (95% CI)
Age group and sexual orientation | Ever use of cigarettes:^b^ % (95% CI) | Cigarettes | Cigars | Smokeless tobacco | Pipes^c^ | E-cigarettes | ≥2 tobacco products^d^ | Attempt in past year^e^ | Quit for ≥6 months^f^
Adults (≥18 years of age) | 35.4 (34.9–35.9) | 12.7 (12.4–13.0) | 3.5 (3.4–3.7) | 2.3 (2.2–2.4) | 1.0 (0.9–1.1) | 4.2 (4.1–4.4) | 3.5 (3.4–3.7) | 55.4 (53.2–57.5) | 8.1 (7.1–9.3)
Heterosexual | 35.4 (34.9–35.9) | 12.5 (12.2–12.8) | 3.5 (3.3–3.7) | 2.4 (2.2–2.5) | 1.0 (0.9–1.0) | 4.0 (3.8–4.1) | 3.4 (3.2–3.6) | 54.4 (52.2–56.6) | 8.0 (6.9–9.2)
Not heterosexual (all)^g^ | 38.0 (36.0–40.0) | 16.3 (14.8–17.9) | 4.3 (3.4–5.4) | 1.0 (0.7–1.5) | 2.3 (1.7–3.1) | 11.2 (9.8–12.8) | 6.5 (5.5–7.8) | 67.3 (57.9–75.5) | 13.1 (8.0–20.9)
Gay | 40.7 (36.7–44.7) | 16.3 (13.2–19.9) | —^h^ | —^h^ | —^h^ | 7.8 (6.0–10.2) | 6.2 (4.0–9.4) | 64.1 (46.4–78.6) | —^h^
Lesbian | 34.5 (30.2–39.0) | 13.4 (10.5–16.9) | 3.3 (1.9–5.7) | —^h^ | —^h^ | 5.9 (4.0–8.5) | 3.9 (2.5–5.9) | —^h^ | —^h^
Bisexual | 39.6 (36.4–42.9) | 18.0 (15.7–20.6) | 5.4 (4.1–7.1) | 1.0 (0.6–1.8) | 2.8 (1.9–4.1) | 15.4 (13.0–18.0) | 8.3 (6.7–10.2) | 71.1 (57.1–82.0) | —^h^
Young adults (18–24 years of age) | 12.2 (11.2–13.3) | 6.9 (6.2–7.7) | 3.7 (3.1–4.3) | 2.0 (1.6–2.5) | 1.8 (1.4–2.2) | 9.9 (9.0–10.8) | 5.1 (4.4–5.8) | 68.5 (58.4–77.1) | 14.6 (9.1–22.6)
Heterosexual | 11.6 (10.6–12.7) | 6.6 (5.8–7.4) | 3.5 (3.0–4.2) | 2.2 (1.8–2.8) | 1.8 (1.4–2.3) | 9.3 (8.4–10.4) | 4.9 (4.3–5.7) | 65.6 (53.9–75.7) | 14.3 (8.3–23.5)
Not heterosexual (all) | 18.2 (14.7–22.2) | 9.7 (7.3–12.9) | 4.2 (2.6–6.7) | —^h^ | —^h^ | 14.3 (11.2–18.0) | 5.5 (3.8–7.8) | —^h^ | —^h^
Gay | —^h^ | —^h^ | —^h^ | N/A | —^h^ | —^h^ | —^h^ | N/A | —^h^
Lesbian | —^h^ | —^h^ | —^h^ | N/A | N/A | —^h^ | —^h^ | —^h^ | N/A
Bisexual | 22.2 (17.5–27.7) | 11.9 (8.5–16.3) | 4.6 (2.7–7.9) | —^h^ | —^h^ | 18.5 (14.0–23.9) | 7.3 (4.9–10.9) | —^h^ | —^h^

Source: NHIS, National Center for Health Statistics, public use data, 2019–2021; ever use of cigarettes and current use of tobacco are based on 2019–2021 data; and smoking cessation outcomes are based on 2020 data.

Notes: CI = confidence interval; N/A = not available.

a People who currently smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes and smoking cigarettes every day or some days at the time of the survey. People who currently used other products (cigars, smokeless tobacco, pipe, e-cigarettes) was defined as those who reported having used such products every day or some days.

b People who had ever smoked cigarettes was defined as those who smoked at least 100 cigarettes in their lifetimes.

c Pipes included use of regular pipes, water pipes, or hookah.

d Any combination of more than one tobacco product.

e Attempt in past year was defined as the percentage of people who (a) currently smoked cigarettes and reported having stopped smoking for more than 1 day during the past 12 months because they were trying to quit smoking and (b) quit smoking during the past year.

f Quit for at least 6 months was defined as the percentage of people who used to smoke cigarettes and reported having quit smoking for ≥6 months during the past year, among people who currently smoked for at least 2 years and people who had quit smoking during the past year.

g Includes people who identified as gay, lesbian, or bisexual or who reported “something else.”

h Unstable estimate is not presented because of a relative standard error >0.3 or number of unweighted denominators <50.

#### Adults

Data from the 2019–2021 NHIS indicate that the prevalence of daily cigarette use among adults was significantly higher among adults who identified with a minoritized sexual orientation group (12.1%; 95% CI, 10.7–13.6) than it was among heterosexual adults (9.6%; 95% CI, 9.3–9.9) (NHIS, public use data, 2019–2021; data not shown in tables). Among adults who currently smoke cigarettes, the percentage of adults smoking 20 or more cigarettes each day was higher among gay adults (48.7%; 95% CI, 36.1–61.2) than it was among heterosexual adults (34.3%; 95% CI, 33.0–35.6). In contrast, the percentage of adults smoking 1–9 cigarettes per day was higher among lesbian adults (41.9%; 95% CI, 27.9–55.9) than it was among heterosexual adults (26.0%; 95% CI, 24.8–27.2). (Figure 2.3).

The prevalence of daily cigarette use among young adults who identified with a minoritized sexual orientation group (6.1%; 95% CI, 4.1–9.1) was similar to that of young adults who were heterosexual (4.2%; 95% CI, 3.6–5.0). However, the prevalence of daily cigarette use was higher among young adults who were bisexual (7.8%; 95% CI, 5.1-12.0) than it was among young adults who were heterosexual (4.2%; 95% CI, 3.6–5.0) (NHIS, public use data, 2019–2021) (data not shown in tables or figures; no gay men 18–24 years of age reported daily cigarette use; estimate for lesbian women suppressed due to small numbers).

### Patterns of Smoking Cessation

According to NHIS data from 2019 to 2021, estimates of making a quit attempt in the past year were higher among adults (18 years of age and older) who identified with a minoritized sexual orientation group (67.3%; 95% CI, 57.9–75.5)—and specifically, adults who were bisexual (71.1%; 95% CI, 57.1–82.0)—than it was among adults who were heterosexual (54.4%; 95% CI, 52.2–56.6). However, estimates of quitting smoking for at least 6 months were similar between adults who were heterosexual (8.0%; 95% CI, 6.9–9.2) and adults who identified with a minoritized sexual orientation group (13.1%; 95% CI, 8.0–20.9) (Table 2.11).

Figure 2.3 Percentage of adults, 18 years of age and older, who currently smoked cigarettes, by sexual orientation and number of cigarettes smoked per day; National Health Interview Survey (NHIS) 2019–2021 combined data, United States

Notes: CI = confidence interval.

^a^All other sexual orientations includes responses from those who reported identifying as gay, lesbian, bisexual, and those who reported “something else.”

During 2019-2021, among lesbian adults who smoked cigarettes, most (42%) smoked 1-9 cigarettes per day. Smoking 10-19 cigarettes per day was most common among bisexual adults who smoked (41%), heterosexual adults who smoked (40%), and adults of all other sexual orientations who smoked (37%). Smoking 20 or more cigarettes per day was most common among gay adults who smoked (49%). Figure note “a” offers more details about the definition of “all other sexual orientations.”

Source: NHIS, National Center for Health Statistics, public use data, 2019–2021.

Among young adults (18–24 years of age), 68.5% (95% CI, 58.4–77.1) overall reported making a quit attempt during the past year, and 14.6% (95% CI, 9.1–22.6) reported quitting smoking for at least 6 months. Among young adults who were heterosexual, 65.6% (95% CI, 53.9–75.7) reported making a quit attempt during the past year and 14.3% (95% CI, 8.3–23.5) reported quitting smoking for at least 6 months. Data on making a quit attempt during the past year and quitting smoking for at least 6 months were suppressed for young adults who identified with a minoritized sexual orientation group (Table 2.11).

### Patterns of Use of Other Tobacco Products

#### E-Cigarettes

##### Youth

Data from the 2019 YRBS indicate that ever use of electronic vapor products (referred to hereafter as e-cigarettes)—including e-cigars, e-pipes, e-hookahs, vaping pens, and hookah pens—was greater among gay, lesbian, or bisexual high school students (56.0%; 95% CI, 52.2–59.7) than heterosexual high school students (49.8%; 95% CI, 47.7–52.0) or high school students who were unsure of their sexual orientation (37.2%; 95% CI, 30.9–43.9) (Table 2.10). The prevalence of past-30-day use of e-cigarettes was greater among gay, lesbian, or bisexual high school students (34.1%; 95% CI, 30.8–37.6) than it was among high school students who were unsure of their sexual orientation (24.9%; 95% CI, 19.8–30.7) but was similar to the prevalence of past-30-day e-cigarette use among heterosexual high school students (32.8%; 95% CI, 30.5–35.2) (Table 2.10). Frequent use of e-cigarettes was similar among high school students who identified as heterosexual (10.8%; 95% CI, 9.4–12.3); gay, lesbian, or bisexual (10.5%; 95% CI, 8.1–13.5); and among those who were unsure of their sexual orientation (8.8%; 95% CI, 6.1–12.6) (CDC n.d.g). Daily use of e-cigarettes was also similar among high school students who identified as heterosexual (7.2%; 95% CI, 6.0–8.6); gay, lesbian, or bisexual (6.7; 95% CI, 4.8–9.3); and among those who were unsure of their sexual orientation (5.9%; 95% CI, 3.6–9.4) (CDC n.d.f).

##### Adults

From 2019 to 2021, NHIS data indicate that ever use of e-cigarettes was significantly higher among adults who identified with a minoritized sexual orientation group (37.8%; 95% CI, 35.7–40.0) than it was among heterosexual adults (16.5%; 95% CI, 16.1–16.9). Among adults who identified with a minoritized sexual orientation group, 31.8% (95% CI, 27.9–36.0) of gay men, 26.7% (95% CI, 22.5–31.4) of lesbian women, and 46.7% (95% CI, 43.4–50.1) of bisexual adults had ever used e-cigarettes (NHIS, public use data, 2019–2021).

Among all adults, current use of e-cigarettes was higher among adults who identified with a minoritized sexual orientation group (11.2%; 95% CI, 9.8–12.8), specifically gay (7.8%; 95% CI, 6.0–10.2) and bisexual (15.4%; 95% CI, 13.0–18.0) adults, than it was among heterosexual adults (4.0%; 95% CI, 3.8–4.1) (Table 2.11).

Among young adults, NHIS data from 2019 to 2021 show that the prevalence of ever e-cigarette use was higher among young adults who identified with a minoritized sexual orientation group (42.1%; 95% CI, 37.4–47.1) than it was among heterosexual young adults (30.3%; 95% CI, 28.7–31.9) (NHIS, public use data, 2019–2021). The prevalence of current e-cigarette use was also higher among young adults who identified with a minoritized sexual orientation group (14.3%; 95% CI, 11.2–18.0) than it was among heterosexual young adults (9.3%; 95% CI, 8.4–10.4). The prevalence of current e-cigarette use among individual groups of people who identified with a minoritized sexual orientation group was suppressed for young adults who identified as gay and lesbian; however, 18.5% (95% CI, 14.0–23.9) of young adults who identified as bisexual reported current e-cigarette use (Table 2.11).

#### Smokeless Tobacco

##### Youth

Data from the 2019 YRBS indicate that the prevalence of current use of smokeless tobacco was similar among high school students who were heterosexual (3.7%; 95% CI, 3.1–4.4); gay, lesbian, or bisexual (3.2%; 95% CI, 2.0–5.2); and high school students who were unsure of their sexual orientation (5.5%; 95% CI, 3.1–9.4) (Table 2.10). Data from the 2017 YRBS indicate that frequent use and daily use of smokeless tobacco did not differ by sexual orientation (Kann et al. 2018).

##### Adults

Ever use of smokeless tobacco among adults was comparable among heterosexual adults (11.0%; 95% CI, 10.7–11.3) and among adults who identified with a minoritized sexual orientation group (10.1%; 95% CI, 8.9–11.4; NHIS, public use data, 2019–2021; data not shown in tables). Current use of smokeless tobacco was higher among heterosexual adults (2.4%; 95% CI, 2.2–2.5) than it was among adults who identified with a minoritized sexual orientation group (1.0%; 95% CI, 0.7–1.5) (Table 2.11).

An estimated 9.0% (95% CI, 8.1–10.1) of heterosexual young adults and 7.0% (95% CI, 4.7–10.3) of young adults who identified with a minoritized sexual orientation group had ever used smokeless tobacco (NHIS, public use data, 2019–2021). The prevalence of current use of smokeless tobacco among heterosexual young adults was 2.2% (95% CI, 1.8–2.8), but data were suppressed for young adults who identified with a minoritized sexual orientation group (Table 2.11).

#### Cigars

##### Youth

Data from the 2019 YRBS indicate that the prevalence of current cigar use was similar among high school students who were heterosexual (5.2%; 95% CI, 4.4–6.1); gay, lesbian, or bisexual (8.1%; 95% CI, 5.9–11.1); and those who were unsure of their sexual orientation (7.2%; 95% CI, 4.3–12.0) (Table 2.10). According to 2019 YRBS data, the prevalence of frequent and daily cigar use was highest among high school students who were unsure of their sexual orientation (3.7%; 95% CI, 1.8–7.4 and 3.2%; 95% CI, 1.5–6.8; respectively); frequent and daily cigar use in this population differed significantly from the prevalence among heterosexual youth (0.8%, 95% CI, 0.5–1.2 and 0.6%, 95% CI, 0.4–0.9, respectively) (CDC n.d.d, n.d.e).

##### Adults

Data from the 2019–2021 NHIS indicate that the prevalence of ever use of cigars (28.2%; 95% CI, 27.6–28.7) was lower among heterosexual adults than it was among adults who identified with a minoritized sexual orientation group (35.4%; 95% CI, 33.4–37.4). Overall, 31.3% (95% CI, 27.1–35.8) of lesbian, 35.1% (95% CI, 31.2–39.1) of gay, and 37.9% (95% CI, 34.7–41.1) of bisexual adults had ever used cigars (NHIS, public use data, 2019–2021). Current use of cigars was similar between heterosexual adults (3.5%; 95% CI, 3.3–3.7) and adults who identified with a minoritized sexual orientation group (4.3%; 95% CI, 3.4–5.4). However, adults identifying as bisexual (5.4%; 95% CI, 4.1–7.1) reported a higher prevalence of current use of cigars compared with heterosexual adults (Table 2.11).

Data from the 2019–2021 NHIS indicate that ever use of cigars was comparable among young adults who identified with a minoritized sexual orientation group (22.4%; 95% CI, 18.6–26.8) and young adults who were heterosexual (20.8%; 95% CI, 19.4–22.2) (NHIS, public use data, 2019–2021). Similarly, current use of cigars was comparable between young adults who identified with a minoritized sexual orientation group (4.2%; 95% CI, 2.6–6.7) and young adults who were heterosexual (3.5%; 95% CI, 3.0–4.2) (Table 2.11).

#### Pipes, Including Hookahs and Water Pipes

##### Youth

Data on pipe use by sexual orientation are not available in the YRBS, but NYTS data show that less than 1% of U.S. middle and high school students reported use of pipes during the past 30 days in 2020, making it difficult to obtain stable estimates among students with different sexual orientations (Gentzke et al. 2020).

Data from the 2020 NYTS indicate that the prevalence of current hookah use was greater among U.S. middle and high school students who were gay, lesbian, or bisexual (4.6%; 95% CI, 3.4–6.1) than it was among students who identified as heterosexual (1.7%; 95% CI, 1.4–2.1); 2.7% (95% CI, 1.5–4.7) of students who were unsure of their sexual orientation reported current hookah use (Gentzke et al. 2020).

##### Adults

More than a quarter of bisexual adults (27.3%; 95% CI, 24.5–30.2) and gay men 25.3% (95% CI, 21.7–29.3) reported ever use of pipes (including regular pipes, water pipes, or hookahs) compared with 18.0% (95% CI, 14.5–22.1) of lesbian women (NHIS, public use data, 2019–2021). Prevalence of current pipe use was lower among heterosexual adults (1.0%; 95% CI, 0.9–1.0) than it was among adults who identified with a minoritized sexual orientation group (2.3%; 95% CI, 1.7–3.1) (Table 2.11).

For young adults, estimates of the prevalence of ever use of pipes were 19.2% (95% CI, 15.2–24.0) for bisexual individuals and 11.2% (95% CI, 10.2–12.3) for heterosexual individuals (NHIS, public use data, 2019–2021; estimates were suppressed for gay, lesbian, and other sexual orientation individuals). The prevalence of current pipe use among heterosexual young adults was 1.8% (95% CI, 1.4–2.3), but data were suppressed for young adults who identified with a minoritized sexual orientation group (Table 2.11).

### Patterns of Polytobacco Use

#### Youth

Data from the 2019 YRBS indicate that use of multiple tobacco products during the past 30 days was similar for high school students who were heterosexual (7.8%; 95% CI, 6.7–9.0), students who were unsure of their sexual orientation (8.1%; 95% CI, 5.4–11.9), and students who were gay, lesbian, or bisexual (10.4%; 95% CI, 8.0–13.5) (Table 2.10).

#### Adults

Data from the 2019–2021 NHIS indicate that current use of two or more tobacco products was lower for heterosexual adults (3.4%; 95% CI, 3.2–3.6) than it was for adults who identified with a minoritized sexual orientation group (6.5%; 95% CI, 5.5–7.8) (Table 2.11). The prevalence of polytobacco use among bisexual adults (8.3%; 95% CI, 6.7–10.2) and gay adults (6.2%; 95% CI, 4.0–9.4) was higher than the prevalence among heterosexual adults (3.4%; 95% CI, 3.2–3.6), while the prevalence among adults who were lesbian (3.9%; 95% CI, 2.5–5.9) was similar to that of heterosexual adults (Table 2.11).

The prevalence of current polytobacco use was similar between young adults who identified with a minoritized sexual orientation group (5.5%; 95% CI, 3.8–7.8) and young adults who were heterosexual (4.9%; 95% CI, 4.3–5.7) (Table 2.11).

### Patterns of Co-Use with Other Substances

Few national studies report on the prevalence of tobacco co-use with other substances by sexual orientation, though several studies have used latent class analyses to identify patterns of substance co-use and the association between sexual orientation and these patterns of co-use. Three studies using national data on adolescents found three patterns of use that captured tobacco use with alcohol and cannabis (Dermody 2018; Coulter et al. 2019; Silveira et al. 2019). In these studies, the odds of tobacco and substance co-use were higher among adolescents who identified as gay, lesbian, or bisexual than the odds of such use among adolescents who identified as heterosexual.

### Tobacco Use by Sexual Orientation and Race and Ethnicity

NHIS data during 2019–2021 highlight differences in tobacco use by sexual orientation and race and ethnicity. Due to small sample sizes, comparisons in current use of tobacco products or cessation behavior were not possible across all racial, ethnic, and sexual orientation populations.

Among Black adults, the prevalence of current e-cigarette use was higher among adults who identified with a minoritized sexual orientation group (including individuals who identified as gay, lesbian, bisexual, or who reported “something else”) (7.0%; 95% CI, 4.1–11.7) than it was among heterosexual adults (2.2%; 95% CI, 1.9–2.7). Current use of two or more tobacco products was also higher among Black adults who identified with a minoritized sexual orientation group (6.5%; 95% CI, 4.0–10.2) than it was among those who were heterosexual (3.1%; 95% CI, 2.7–3.6) (Table 2.12).

Among Hispanic adults, the prevalence of current use of e-cigarettes was higher among adults who identified with a minoritized sexual orientation group (10.7%; 95% CI, 7.6–14.8) than it was among heterosexual adults (2.7%; 95% CI, 2.4–3.1). Hispanic adults who identified with a minoritized sexual orientation group also reported a higher prevalence of current use of two or more tobacco products (4.4%; 95% CI, 2.6–7.4) compared with heterosexual Hispanic adults (2.1%; 95% CI, 1.8–2.4).

Among White adults, the prevalence of current cigarette use was higher among adults who identified with a minoritized sexual orientation group (16.7%; 95% CI, 14.9–18.6) than it was among heterosexual adults (13.8%; 95% CI, 13.4–14.2). Additionally, the prevalence of current e-cigarette use and current use of two or more tobacco products was higher among White adults who identified with a minoritized sexual orientation group than it was among those who were heterosexual: current e-cigarette use (minoritized sexual orientation group: 11.4%; 95% CI, 9.8–13.4 vs. heterosexual: 4.6%; 95% CI, 4.3–4.8) and current use of two or more tobacco products (minoritized sexual orientation group: 6.2%; 95% CI, 5.1–7.5 vs. heterosexual: 3.8%; 95% CI, 3.6–4.1). However, among White adults, the prevalence of current smokeless tobacco use was higher among heterosexual adults (3.3%; 95% CI, 3.1–3.5) than it was among adults who identified with a minoritized sexual orientation group (1.1%; 95% CI, 0.7–1.8).

Among adults who identified with “Other” or multiple races, the prevalence of current e-cigarette use was higher among adults who identified with a minoritized sexual orientation group (18.4%; 95% CI, 11.5–28.0) than it was among heterosexual adults (7.4%; 95% CI, 5.9–9.3).

### Patterns of Tobacco Product Use by Gender Identity

#### Youth

Gender identity was not measured in the 2019 YRBS. However, the NYTS first assessed gender identity during the 2021 administration (Gentzke et al. 2022). Based on data from the 2021 NYTS, a higher percentage of U.S. middle and high school students who identified as transgender (37.9%; 95% CI, 31.3–45.0) had ever used any tobacco product compared with those who reported they were not transgender (23.4%; 95% CI, 21.3–25.7). In addition, 26.4% (95% CI, 20.7–33.1) of students who were unsure about their gender identity reported ever use of any tobacco product (Gentzke et al. 2022). An estimated 18.9% (95% CI, 13.8–25.4) of students who identified as transgender reported current (during the past 30 days) use of any tobacco product compared with 8.2% (95% CI, 7.3–9.3) of students who reported they were not transgender and 9.1% (95% CI, 6.1–13.5) of students who were unsure about their gender identity (Gentzke et al. 2022).

Table 2.12 Prevalence of ever use of cigarettes, current use of tobacco products, and smoking cessation among adults, 18 years of age and older, by sexual orientation and race and ethnicity; National Health Interview Survey (NHIS) 2019–2021 combined data, United States

Sexual orientation and race and ethnicity | Ever use of cigarettes:^b^ % (95% CI) | Current use of tobacco products:^a^ % (95% CI) | | | | | | Smoking cessation (2020): % (95% CI)
Sexual orientation and race and ethnicity | Ever use of cigarettes:^b^ % (95% CI) | Cigarettes | Cigars | Smokeless tobacco | Pipes^c^ | E-cigarettes | ≥2 tobacco products^d^ | Attempt in past year^e^ | Quit for ≥6 months^f^
Heterosexual | 35.4 (34.9–35.9) | 12.5 (12.2–12.8) | 3.5 (3.3–3.7) | 2.4 (2.2–2.5) | 1.0 (0.9–1.0) | 4.0 (3.8–4.1) | 3.4 (3.2–3.6) | 54.4 (52.2–56.6) | 8.0 (6.9–9.2)
American Indian and Alaska Native | 45.7 (37.5–54.1) | 22.1 (16.0–29.7) | 3.6 (2.1–5.9) | 5.4 (3.6–8.0) | —^g^ | 3.8 (2.2–6.7) | 6.9 (4.6–10.3) | 49.0 (32.4–65.9) | —^g^
Asian | 18.9 (17.5–20.4) | 6.6 (5.7–7.6) | 1.1 (0.8–1.5) | 0.5 (0.3–0.8) | 0.7 (0.5–1.1) | 2.9 (2.3–3.6) | 1.5 (1.1–2.0) | 67.4 (56.5–76.7) | —^g^
Black | 26.9 (25.8–28.2) | 13.6 (12.6–14.5) | 4.7 (4.1–5.3) | 0.8 (0.5–1.1) | 1.5 (1.2–1.9) | 2.2 (1.9–2.7) | 3.1 (2.7–3.6) | 61.3 (54.8–67.5) | 6.7 (4.6–9.7)
Hispanic | 23.2 (22.3–24.2) | 8.1 (7.5–8.7) | 2.5 (2.2–2.9) | 0.6 (0.5–0.8) | 0.8 (0.6–1.0) | 2.7 (2.4–3.1) | 2.1 (1.8–2.4) | 56.0 (49.3–62.5) | 6.3 (3.8–10.3)
Other and multiple races | 39.4 (36.5–42.4) | 17.3 (15.0–19.9) | 4.4 (3.2–6.2) | 2.5 (1.7–3.6) | —^g^ | 7.4 (5.9–9.3) | 6.3 (4.7–8.5) | 54.5 (40.2–68.1) | —^g^
White | 41.5 (40.9–42.0) | 13.8 (13.4–14.2) | 3.7 (3.5–4.0) | 3.3 (3.1–3.5) | 0.9 (0.8–1.0) | 4.6 (4.3–4.8) | 3.8 (3.6–4.1) | 52.3 (49.7–54.9) | 8.7 (7.3–10.2)
Not heterosexual (all) ^h^ | 38.0 (36.0–40.0) | 16.3 (14.8–17.9) | 4.3 (3.4–5.4) | 1.0 (0.7–1.5) | 2.3 (1.7–3.1) | 11.2 (9.8–12.8) | 6.5 (5.5–7.8) | 67.3 (57.9–75.5) | 13.1 (8.0–20.9)
American Indian and Alaska Native | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | N/A | N/A
Asian | 22.7 (15.0–32.8) | 11.5 (6.5–19.5) | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | N/A
Black | 27.0 (21.9–32.7) | 16.5 (12.6–21.4) | 6.4 (4.0–10.0) | —^g^ | —^g^ | 7.0 (4.1–11.7) | 6.5 (4.0–10.2) | —^g^ | —^g^
Hispanic | 26.3 (21.6–31.5) | 11.9 (8.3–16.8) | 3.3 (1.8–5.7) | —^g^ | —^g^ | 10.7 (7.6–14.8) | 4.4 (2.6–7.4) | —^g^ | —^g^
Other and multiple races | 47.9 (37.3–58.7) | 25.3 (15.9–37.7) | —^g^ | —^g^ | —^g^ | 18.4 (11.5–28.0) | —^g^ | —^g^ | —^g^
White | 42.4 (39.9–44.9) | 16.7 (14.9–18.6) | 4.1 (3.2–5.4) | 1.1 (0.7–1.8) | 1.4 (0.9–2.1) | 11.4 (9.8–13.4) | 6.2 (5.1–7.5) | 60.6 (49.2–70.9) | 16.0 (9.1–26.4)
Gay | 40.7 (36.7–44.7) | 16.3 (13.2–19.9) | —^g^ | —^g^ | —^g^ | 7.8 (6.0–10.2) | 6.2 (4.0–9.4) | 64.1 (46.4–78.6) | —^g^
American Indian and Alaska Native | —^g^ | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Asian | —^g^ | —^g^ | N/A | —^g^ | N/A | —^g^ | —^g^ | —^g^ | N/A
Black | 33.3 (21.5–47.6) | 20.0 (11.3–33.0) | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^
Hispanic | 28.8 (20.5–38.8) | 12.5 (7.4–20.5) | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^
Other and multiple races | —^g^ | —^g^ | —^g^ | N/A | —^g^ | —^g^ | —^g^ | —^g^ | N/A
White | 44.3 (39.8–48.9) | 15.7 (12.7–19.4) | 2.4 (1.4–3.9) | —^g^ | —^g^ | 7.9 (5.8–10.6) | 4.7 (3.2–7.0) | —^g^ | —^g^
Lesbian | 34.5 (30.2–39.0) | 13.4 (10.5–16.9) | 3.3 (1.9–5.7) | —^g^ | —^g^ | 5.9 (4.0–8.5) | 3.9 (2.5–5.9) | —^g^ | —^g^
American Indian and Alaska Native | —^g^ | —^g^ | N/A | N/A | N/A | —^g^ | N/A | N/A | N/A
Asian | —^g^ | —^g^ | N/A | N/A | N/A | —^g^ | —^g^ | —^g^ | N/A
Black | 21.4 (14.1–31.0) | —^g^ | —^g^ | N/A | —^g^ | —^g^ | —^g^ | —^g^ | —^g^
Hispanic | 26.2 (17.0–38.1) | —^g^ | —^g^ | —^g^ | N/A | —^g^ | —^g^ | —^g^ | N/A
Other and multiple races | —^g^ | —^g^ | —^g^ | N/A | N/A | —^g^ | —^g^ | N/A | N/A
White | 39.3 (33.6–45.3) | 14.3 (10.5–19.2) | —^g^ | —^g^ | —^g^ | 4.7 (2.9–7.5) | —^g^ | —^g^ | —^g^
Bisexual | 39.6 (36.4–42.9) | 18.0 (15.7–20.6) | 5.4 (4.1–7.1) | 1.0 (0.6–1.8) | 2.8 (1.9–4.1) | 15.4 (13.0–18.0) | 8.3 (6.7–10.2) | 71.1 (57.1–82.0) | —^g^
American Indian and Alaska Native | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | N/A | N/A
Asian | —^g^ | —^g^ | N/A | N/A | —^g^ | —^g^ | —^g^ | —^g^ | N/A
Black | 28.4 (19.9–38.9) | 19.4 (12.8–28.2) | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^
Hispanic | 28.7 (21.2–37.6) | 15.4 (9.3–24.5) | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | —^g^ | N/A
Other and multiple races | 50.4 (37.0–63.8) | 23.9 (15.0–35.9) | —^g^ | —^g^ | —^g^ | 23.9 (13.7–38.3) | —^g^ | —^g^ | —^g^
White | 43.7 (39.8–47.7) | 18.1 (15.4–21.1) | 5.8 (4.2–8.1) | —^g^ | —^g^ | 15.5 (12.6–18.8) | 8.3 (6.4–10.7) | 68.5 (51.1–81.9) | —^g^

Source: NHIS, National Center for Health Statistics, public use data, 2019–2021; ever use of cigarettes and current use of tobacco are based on 2019–2021 data; and smoking cessation outcomes are based on 2020 data.

Notes: CI = confidence interval; N/A = not available.

a People who currently smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes and smoking cigarettes every day or some days at the time of the survey. People who currently used other products (cigars, smokeless tobacco, pipe, e-cigarettes) was defined as those who reported having used such products every day or some days.

b People who had ever smoked cigarettes was defined as those who smoked at least 100 cigarettes in their lifetimes.

c Pipes included use of regular pipes, water pipes, or hookah.

d Any combination of more than one tobacco product.

e Percentage of people who (a) currently smoked cigarettes and reported having stopped smoking for more than 1 day during the past 12 months because they were trying to quit smoking and (b) quit smoking during the past year.

f Quit for at least 6 months was defined as the percentage of people who used to smoke cigarettes and reported having quit smoking for at least 6 months during the past year, among people who currently smoked for at least 2 years and people who had quit smoking during the past year.

g Unstable estimate is not presented because of a relative standard error >0.3 or number of unweighted denominators <50.

h Includes people who identified as gay, lesbian, or bisexual or who reported “something else.”

#### Adults

Gender identity was not measured in the 2019–2021 NHIS; however, it was added to the survey beginning in 2022 (National Center for Health Statistics 2022). According to data analyzed from Wave 2 of the PATH Study (fielded October 2014–October 2015), a higher prevalence of current use of cigarettes, e-cigarettes, or cigars was reported among transgender adults (33.0%; 95% CI, 24.3–41.7) compared with cisgender adults (23.8%; 95% CI, 23.2–24.4; p = 0.021). However, in multivariable-adjusted analyses, transgender identity was not associated with the use of tobacco products (Wheldon and Wiseman 2019). This finding contrasts with a previous study that found transgender adults use tobacco products at a higher prevalence compared with cisgender adults in adjusted analyses (Buchting et al. 2017).

## Tobacco Use by Socioeconomic Status

In the United States, SES is typically measured by indicators of income (e.g., annual family income in dollars) or educational attainment (e.g., years of schooling or degrees earned). Regardless, SES is a complex construct that includes multiple dimensions of different health advantages and disadvantages. Lower SES is associated with unhealthy behaviors, and disparities in tobacco use exist in a gradient across SES levels (NCI 2017).

Despite declines in current cigarette use over time, adults with 9–12 years of education (but no diploma) and adults with a high school diploma or General Educational Development (GED) equivalent have consistently reported a higher prevalence of current cigarette use (Figure 2.4). Furthermore, disparities in the prevalence of smoking by educational attainment have increased over time. For example, in 1970, the prevalence of smoking among people with 9–12 years of education (but no diploma) was 15.8 percentage points higher than those with a college degree (44.6% vs. 28.8%). However, in 2018, the gap in the prevalence of smoking among people with 9–12 years of education (but no diploma) and those with a college degree increased to 21.7 percentage points (27.5% vs. 5.8%, respectively). Thus, the smoking prevalence ratio between those with a 9th- to 12th-grade education (but no diploma) and those with a college degree has increased by nearly 1.5 times over 50 years (Figure 2.4).

Prior research has shown that the prevalence of smoking in the U.S. population follows an educational gradient, where those with higher levels of educational attainment have lower rates of smoking and those with lower levels of educational attainment have higher rates of smoking (Pampel 2009; Ho and Fenelon 2015). However, these earlier data often used a single category for all people with less than a high school education. When this group is disaggregated into (a) those with an eighth-grade education or less and (b) those with 9–12 years of education (but no diploma), estimates of the prevalence of smoking do not follow this gradient.

Cao and colleagues (2018, 2023) found that people with less than an eighth-grade education had the secondlowest prevalence of smoking after college graduates. This may be due to demographic changes in people with less than an 8th-grade education, which includes an increasing proportion of people who are Hispanic and foreign-born, particularly individuals who were born in Mexico and Central America (Gambino 2017; Cao et al. 2023). As previously described in this chapter, these population groups, overall, have relative low rates of smoking (Cao et al. 2023). The proportion of the adult population that has completed high school or obtained a college degree by 25 years of age has increased steadily over time.

Even as levels of educational attainment have increased over the past several decades, the relative prevalence ranking of each educational group has remained largely the same. People with 9–12 years of education (but no diploma) have had the highest prevalence of smoking of any educational attainment category over the past several decades, and college graduates have consistently had the lowest prevalence of smoking (Cao et al. 2018).

This section focuses on tobacco use by SES among adults, with SES defined in multiple ways. Household income in relationship to the federal poverty level, which is published annually by the U.S. Census Bureau, is used primarily to create a categorical measure of SES (i.e., low, medium, or high). Low SES is defined as having a household income below the federal poverty level, medium SES is defined as having a household income equal to or up to nearly twice the federal poverty level, and high SES is defined as having a household income at least twice the federal poverty level or higher. Patterns in current cigarette smoking are also persistent by poverty status, as people living below the poverty level have a higher prevalence of cigarette smoking than people living at or above the poverty level (Figure 2.5).

Figure 2.4 Prevalence of current cigarette smoking^a^ a People who reported having smoked at least 100 cigarettes during their lifetimes and who, at the time of the interview, reported smoking “every day” or “some days.” among adults, 25 years of age and older, by level of educational attainment;^b^ b Reporting format for level of educational attainment and smoking and tobacco use changed in 2016 for articles appearing in Morbidity and Mortality Weekly Report. Analyses are restricted to respondents 25 years of age and older. National Health Interview Survey (NHIS) 1970–2021,^c^ c The NHIS underwent a redesign in 2019. Because of the changes in weighting and design methodology, direct comparisons between estimates beginning in 2019 and earlier years should be made with caution because the effects of these changes have not been fully evaluated yet. This change is represented by a break in the trend lines between 2018 and 2019. United States

Notes: GED = General Educational Development.

^d^For the Overall category, data on level of educational attainment were not reported for 1971–1973, 1975–1977, 1979, 1981, 1982, 1984, 1986, 1988, 1989, and 1996.

^e^Data for the specific levels of educational attainment were not reported for 1971–1973, 1975–1977, 1979, 1981, 1982, 1984, 1986, 1988, 1989, and 1996.

^f^For 2019–2021, data could not be broken out because of how the education variable was recoded.

The prevalence of current cigarette smoking among adults, 25 year of age and older, generally trended lower from 1970 to 2021, despite periods of variability, overall and among those at all levels of education: Overall, from 37% in 1970 to 12% in 2021; with 8 or fewer years of education, from 33% in 1970 to 12% in 2018; with 9-12 years of education but no diploma, from 45% in 1970 to 28% in 2018; with a high school diploma or GED, from 39% in 1970 to 18% in 2021; with some college education, from 39% in 1970 to 15% in 2021; and with at least a college degree, from 29% in 1970 to 5% in 2021. Figure notes “d,” “e,” and “f” offer more details about the definitions of levels of educational attainment.

Source: NHIS, National Center for Health Statistics, public use data, 1970–2021.

Data on youth are not presented in this section because of the lack of a reliable measure of SES for this age group. The YRBS—the principal source for data on youth used in this report—does not include a measure of SES.

### Patterns of Ever and Current Use of Cigarettes

According to data from the NHIS, in 2020, people with the highest self-reported income (>$100,000 annual household income) had roughly one-third the prevalence of smoking (6.2%; 95% CI, 5.6–6.9) of those with the lowest household incomes (<$35,000) (20.2%; 95% CI, 19.0–21.4) (Table 2.13). Furthermore, tobacco use has consistently been 5–10 percentage points higher among people living below the federal poverty level (Figure 2.5).

The prevalence of ever use of cigarettes among all adults during 2019–2021 was higher in the medium-SES group (39.2%; 95% CI, 38.2–40.3) and low-SES group (39.1%; 95% CI, 37.7–40.6) than it was in the high-SES group (33.9%; 95% CI, 33.4–34.4), as defined by poverty level (Table 2.14). Current cigarette use varied by SES, as defined by poverty level, with the highest prevalence observed in the low-SES group (22.0%; 95% CI, 20.9–23.2), followed by the medium-SES group (18.1%; 95% CI, 17.4–18.9); the prevalence estimate for the high-SES group (10.0%; 95% CI, 9.7–10.3) was about half that of the low-SES group.

Figure 2.5 Trends in the prevalence of current cigarette smoking^a^ a People who reported having smoked 100 or more cigarettes during their lifetime and who, at the time of the interview, reported smoking “every day” or “some days.” among adults, 18 years of age and older, by poverty status;^b^ b Based on self-reported family income and poverty thresholds published by the U.S. Census Bureau (n.d.b). National Health Interview Survey 1965–2021,^c^ c For the Overall category, data for poverty status were not reported for 1966–1969, 1971–1973, 1975–1977, 1979, 1981, 1982, 1984, 1986, 1988, 1989, and 1996. Data on the specific levels of poverty status were collected starting in 1983. Thereafter, data on the specific levels of poverty status were not reported for 1984, 1986, 1988, 1989, and 1996. ^,d^ d The NHIS underwent a redesign in 2019. Because of the changes in weighting and design methodology, direct comparisons between estimates beginning in 2019 and earlier years should be made with caution because the effects of these changes have not been fully evaluated yet. This change is represented by a break in the trend lines between 2018 and 2019. United States

^e^Data for poverty level unknown are not available for 2019–2021.

The prevalence of current cigarette smoking among adults generally trended lower from 1965 to 2021, despite periods of variability, overall and among those at all levels of poverty status: Overall, from 42% in 1965 to 12% in 2021; at or above the poverty level, from 32% in 1983 to 11% in 2021; below the poverty level, from 40% in 1983 to 21% in 2021; and poverty level unknown, from 42% in 1965 to 13% in 2018. Figure note “e” offers more details about the dataset for poverty level unknown.

Source: NHIS, National Center for Health Statistics, public use data, 1965–2021.

Table 2.13 Percentage of current cigarette smoking among adults^a^ overall and by annual household income,^b^ National Health Interview Survey (NHIS) 2019–2020, United States

Year | Overall: % (95% CI) | <$35,000: % (95% CI) | $35,000–74,999: % (95% CI) | $75,000–99,999: % (95% CI) | ≥$100,000: % (95% CI)
2019 | 14.0 (13.4–14.5) | 21.4 (20.3–22.6) | 15.7 (14.8–16.7) | 11.4 (10.1–12.7) | 7.1 (6.4–7.8)
2020 | 12.5 (11.9–13.0) | 20.2 (19.0–21.4) | 14.1 (13.1–15.1) | 10.5 (9.3–11.9) | 6.2 (5.6–6.9)

Source: NHIS, National Center for Health Statistics, public use data, 2019–2020.

Notes: CI = confidence interval.

a People who currently smoked included adults who reported having smoked at least 100 cigarettes in their lifetimes and specified that they currently smoked “every day” or “some days.”

b Based on self-reported family income and poverty thresholds published by the U.S. Census Bureau (n.d.b).

Table 2.14 Prevalence of ever use of cigarettes and current use of tobacco products among adults (≥18 years of age) and young adults (18–24 years of age), by socioeconomic status;^a^ National Health Interview Survey (NHIS) 2019–2021, United States

Age group and socioeconomic status | Ever use of cigarettes:^c^ % (95% CI) | Current use of tobacco products:^b^ % (95% CI)
Age group and socioeconomic status | Ever use of cigarettes:^c^ % (95% CI) | Cigarettes | Cigars | Smokeless tobacco | Pipes^d^ | E-cigarettes | ≥2 tobacco products^e^
Adults (≥18 years of age)
Overall | 35.4 (34.9–35.9) | 12.7 (12.4–13.0) | 3.5 (3.4–3.7) | 2.3 (2.2–2.4) | 1.0 (0.9–1.1) | 4.2 (4.1–4.4) | 3.5 (3.4–3.7)
Low (< the poverty level) | 39.1 (37.7–40.6) | 22.0 (20.9–23.2) | 3.3 (2.9–3.8) | 1.9 (1.5–2.3) | 1.3 (1.0–1.6) | 4.9 (4.4–5.5) | 4.8 (4.3–5.5)
Medium (1–<2 times the poverty level) | 39.2 (38.2–40.3) | 18.1 (17.4–18.9) | 3.3 (3.0–3.7) | 2.0 (1.8–2.3) | 1.3 (1.0–1.5) | 4.8 (4.4–5.3) | 4.6 (4.2–5.0)
High (≥2 times the poverty level) | 33.9 (33.4–34.4) | 10.0 (9.7–10.3) | 3.6 (3.4–3.8) | 2.4 (2.3–2.6) | 0.9 (0.8–1.0) | 4.0 (3.8–4.2) | 3.1 (2.9–3.3)
Young adults (18–24 years of age)
Overall | 12.2 (11.2–13.3) | 6.9 (6.2–7.7) | 3.7 (3.1–4.3) | 2.0 (1.6–2.5) | 1.8 (1.4–2.2) | 9.9 (9.0–10.8) | 5.1 (4.4–5.8)
Low (< the poverty level) | 12.2 (10.0–14.9) | 8.2 (6.4–10.5) | 3.4 (2.2–5.1) | —^f^ | 1.7 (0.9–3.0) | 8.9 (7.0–11.3) | 4.8 (3.4–6.7)
Medium (1–<2 times the poverty level) | 14.7 (12.5–17.2) | 9.6 (7.9–11.6) | 4.1 (3.0–5.5) | 1.7 (1.0–2.8) | 2.3 (1.5–3.5) | 11.2 (9.3–13.5) | 5.8 (4.5–7.5)
High (≥2 times the poverty level) | 11.3 (10.2–12.6) | 5.6 (4.8–6.6) | 3.6 (2.9–4.4) | 2.4 (1.8–3.1) | 1.6 (1.2–2.2) | 9.6 (8.5–10.8) | 4.9 (4.1–5.8)

Source: NHIS, National Center for Health Statistics, public use data, 2019–2021.

Notes:CI = confidence interval.

a Socioeconomic status was assessed by calculating the ratio of family income to the corresponding poverty threshold.

b People who currently smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes and smoking cigarettes every day or some days at the time of the survey. People who currently used other products (cigars, smokeless tobacco, pipe, e-cigarettes) was defined as those who reported having used such products every day or some days at the time of the survey.

c People who had ever smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes.

d Pipes included use of regular pipes, water pipes, or hookah.

e Any combination of more than one tobacco product.

f Unstable estimate is not presented because of a relative standard error >0.3 or number of unweighted denominators <50.

The prevalence of ever use of cigarettes among young adults during 2019–2021 was similar across SES groups (Table 2.14). Current cigarette use was lower in the high-SES (5.6%; 95% CI, 4.8–6.6) group than it was in the medium-SES group (9.6%; 95% CI, 7.9–11.6).

### Patterns in Frequency and Quantity of Cigarette Use

Prior studies using U.S. samples have reported that SES is inversely related to the frequency of cigarette smoking in adults, with people with higher levels of education being less likely to smoke daily (Hennrikus et al. 1996; Shiffman et al. 2014; Wang et al. 2018). The prevalence of daily cigarette use among adults overall during 2019–2021 was greater among people in the low-SES (17.2%; 95% CI, 16.2–18.2) and medium-SES (14.4%; 95% CI, 13.7–15.2) groups than it was among those in the high-SES group (7.4%; 95% CI,7.2–7.7) (NHIS, public use data, 2019–2021). Among adults in the low-SES group who currently smoke, a higher percentage currently smoke 10–19 cigarettes each day (37.8%; 95% CI, 34.9–40.8) compared with the percentage who currently smoke 1–9 cigarettes each day (28.5%; 95% CI, 25.7–31.3) (Figure 2.6). The prevalence of daily cigarette use among young adults in 2019–2021 was similar in the low-SES (4.8%; 95% CI, 3.4-6.8), medium-SES (6.9%; 95% CI, 5.5-8.7), and high-SES groups (3.3%; 95% CI, 2.7–4.2) (NHIS, public use data, 2019–2021). Among young adults who currently smoke in the high-SES group, a lower percentage currently smoke 20 or more cigarettes each day (17.9%; 95% CI, 10.2–25.6) compared with 1–9 (40.3%; 95% CI, 29.0–51.6) or 10–19 (41.8%; 95% CI, 30.4–53.2) cigarettes each day (Figure 2.7).

### Patterns of Use for Other Tobacco Products

#### E-Cigarettes

The prevalence of ever use of e-cigarettes among adults in 2019–2021 was lower in the high-SES group (16.5%; 95% CI, 16.1–16.9) than it was in the low-SES group (20.3%; 95% CI, 19.1–21.5) and middle-SES group (18.7%; 95% CI, 17.9–19.6) (NHIS, public use data, 2019–2021). Overall, current use of e-cigarettes among adults was 4.2% (95% CI, 4.1–4.4), with a higher prevalence in the low-SES (4.9%; 95% CI, 4.4–5.5) and medium-SES (4.8%; 95% CI, 4.4–5.3) groups than in the high-SES group (4.0%; 95% CI, 3.8–4.2) (Table 2.14).

The prevalence of ever use of e-cigarettes during 2019–2021 was higher among young adults (31.2%; 95% CI, 29.7–32.7) than it was among adults overall (17.3%; 95% CI, 16.9–17.7) (NHIS, public use data, 2019–2021). Current use of e-cigarettes among young adults overall was 9.9% (95% CI, 9.0–10.8). In addition, among young adults, current e-cigarette use was similar across SES groups, ranging from 8.9% (95% CI, 7.0–11.3) in the low-SES group to 11.2% (95% CI, 9.3–13.5) in the medium-SES group (Table 2.14).

#### Smokeless Tobacco

The prevalence of ever use of smokeless tobacco among adults overall during 2019–2021 was 10.9% (95% CI, 10.6–11.2) (NHIS, public use data, 2019–2021). Current use of smokeless tobacco among adults overall was 2.3% (95% CI, 2.2–2.4). Current use of smokeless tobacco among adults was similar across SES groups, ranging from 1.9% (95% CI, 1.5–2.3) in the low-SES group to 2.4% (95% CI, 2.3–2.6) in the high-SES group (Table 2.14).

The prevalence of ever use of smokeless tobacco among young adults during 2019–2020 was lowest among people in the low-SES group (6.3%; 95% CI, 4.5–8.6) and highest among people in the high-SES group (9.6%; 95% CI, 8.5–10.9) (NHIS, public use data, 2019–2021). Overall, current use of smokeless tobacco among young adults was 2.0% (95% CI, 1.6–2.5). Current use of smokeless tobacco among young adults was similar in medium-SES (1.7%; 95% CI, 1.0–2.8) and high-SES (2.4%; 95% CI, 1.8–3.1) groups; data were suppressed for young adults in the low-SES group (Table 2.14).

#### Cigars

During 2019–2021, adults in the high-SES group (30.4%; 95% CI, 29.8–30.9) had the highest prevalence of ever cigar use by SES; the estimates were 23.9% (95% CI, 22.9–24.8) for the medium-SES group and 22.1% (95% CI, 20.9–23.3) for the low-SES group (NHIS, public use data, 2019–2021). Overall, current use of cigars among adults was 3.5% (95% CI, 3.4–3.7). Current use of cigars was similar across the three SES groups, ranging from 3.3% in the low-SES (95% CI, 2.9–3.8) and medium-SES (95% CI, 3.0–3.7) groups to 3.6% (95% CI, 3.4–3.8) in the high-SES group (Table 2.14).

Ever use of cigars during 2019–2021 was similar among young adults in the high-SES group (21.1%; 95% CI, 19.6–22.6), middle-SES group (20.2%; 95% CI, 17.7–23.0), and low-SES group (20.8%; 95% CI, 17.8–24.3) (NHIS, public use data, 2019–2021). Current use of cigars among young adults was 3.7% (95% CI, 3.1–4.3). Current use of cigars among young adults was similar across the three levels of SES, ranging from 3.4% (95% CI, 2.2–5.1) in the low-SES group to 4.1% (95% CI, 3.0–5.5) in the medium-SES group (Table 2.14).

Figure 2.6 Percentage of adults, 18 years of age and older, who currently smoked, by socioeconomic status and number of cigarettes smoked per day; National Health Interview Survey (NHIS) 2019–2021 combined data, United States

During 2019-2021, smoking 10-19 cigarettes per day was the most common quantity smoked among adults in each socioeconomic status group (low, medium, and high socioeconomic status, based on poverty level), ranging from 38% to 40% of adults who currently smoked. Smoking 1-9 was the least common quantity smoked among adults in each socioeconomic status group, ranging from 25% to 29% of adults who currently smoked. Smoking 20 or more cigarettes per day differed only slightly across adults in each socioeconomic status group, ranging from 34% to 35%.

Source: NHIS, National Health Interview Survey, public use data, 2019–2021.

Figure 2.7 Percentage of young adults, 18–24 years of age, who currently smoked, by socioeconomic status and number of cigarettes smoked per day; National Health Interview Survey (NHIS) 2019–2021 combined data, United States

^a^Unstable estimate is not presented for those who currently smoked 20 or more cigarettes per day because of a relative standard error >0.3 or an unweighted denominator <50.

During 2019-2021, across socioeconomic levels (i.e., low, medium, and high socioeconomic status, based on poverty level), 40-42% of young adults 18-24 years of age who currently smoked, smoked 1-9 cigarettes per day, 36-42% smoked 10-19 cigarettes per day, and 18-28% smoked 20 or more cigarettes per day. Figure note “a” offers more details about the dataset for low socioeconomic status.

Source: NHIS, National Health Interview Survey, public use data, 2019–2021.

#### Pipes, Including Hookahs and Water Pipes

Ever use of pipes, including water pipe tobacco or hookahs, among adults overall during 2019–2021 was highest in the high-SES group (14.7%; 95% CI, 14.3–15.1); the prevalence was 12.3% (95% CI, 11.6–13.0) for the medium-SES group and 10.4% (95% CI, 9.5–11.3) for the low-SES group (NHIS, public use data, 2019–2021). Overall, current use of pipes among adults was 1.0% (95% CI, 0.9–1.1). Current pipe use among adults was similar in the low-SES (1.3%; 95% CI, 1.0–1.6), medium-SES (1.3%; 95% CI, 1.0–1.5), and high-SES groups (0.9%; 95% CI, 0.8–1.0) (Table 2.14).

The prevalence of ever use of pipes during 2019–2021 was higher among adults overall (13.8%; 95% CI, 13.5–14.2) than it was among young adults (11.7%; 95% CI, 10.8–12.8) (NHIS Public use data, 2019–2021); ever use of pipes was similar across the three levels of SES. Overall, current use of pipes among young adults was 1.8% (95% CI, 1.4–2.2). Current use of pipes among young adults was similar across the three SES groups, ranging from 1.6% (95% CI, 1.2–2.2) in the high-SES group to 2.3% (95% CI, 1.5–3.5) in the medium-SES group (Table 2.14).

### Patterns of Polytobacco Use

The prevalence of current use of two or more tobacco products was 3.5% (95% CI, 3.4–3.7) among all adults and 5.1% (95% CI, 4.4–5.8) among young adults during 2019–2021. Prevalence was higher among all adults in the low-SES (4.8%; 95% CI, 4.3–5.5) and medium-SES (4.6%; 95% CI, 4.2–5.0) groups than it was among those in the high-SES group (3.1%; 95% CI, 2.9–3.3) (Table 2.14). Among young adults, current polytobacco use was similar across the three SES groups, ranging from 4.8% (95% CI, 3.4–6.7) in the low-SES group to 5.8% (95% CI, 4.5–7.5) in the medium-SES group (Table 2.14).

### Tobacco Use by Socioeconomic Status and Sex

NHIS data from 2019 to 2021 show that, for all tobacco use measures and all levels of SES, the prevalence of use was significantly higher among men than it was among women, except for use of pipes and e-cigarettes among adults in the low-SES group (Table 2.15). Disparities by sex and SES varied by tobacco product. The absolute difference by sex in the prevalence of ever cigarette use was highest for adults in the medium-SES group (13.1 percentage points) compared with those in the low- and high-SES groups (about 10 percentage points in each group). The prevalence of current cigarette use was 5.7 percentage points higher among men than it was among women in the low-SES group and 5.6 percentage points higher among men than it was among women in the medium-SES group; in the high-SES group, the prevalence of current cigarette use was 2.8 percentage points higher among men than it was among women. For cigars, smokeless tobacco, and e-cigarettes, the absolute difference in the prevalence of use between men and women was most pronounced in the high-SES group. The absolute differences in the prevalence of use of pipes and multiple tobacco products between men and women were similar across SES levels.

### Tobacco Use by Socioeconomic Status and Race and Ethnicity

Prior studies have highlighted the complexity of the intersectional relationship of race and ethnicity, income, and tobacco use (Epperson et al. 2022). Data from the 2019–2021 NHIS showed that ever use of cigarettes was highest among American Indian and Alaska Native people and White people in each of the SES groups (Table 2.16).

Within each SES level as defined by poverty level, current use of cigarettes was highest among White people (30.4%; 95% CI, 28.6–32.3) and people who identified as “Other” and multiple races (30.9%; 95% CI, 24.1–38.7) of low SES and American Indian and Alaska Native people of medium (29.9%; 95% CI, 18.9–43.9) and high (18.2%; 95% CI, 12.6–25.5) SES (Table 2.16). Comparisons across all SES and racial and ethnic groups were not possible for other tobacco products due to small numbers in some cells.

### Tobacco Use by Socioeconomic Status and Sexual Orientation

Using 2019–2021 NHIS data, the prevalence of ever use and current use of cigarettes was higher among adults who identified with a minoritized sexual orientation group than it was among adults who identified as heterosexual across all SES categories, although CIs overlapped in some instances (Table 2.17). The general inverse gradient of SES and smoking held when examining current cigarette smoking across sexual orientation, whereby the prevalence of cigarette use was higher among adults who identified with a minoritized sexual orientation group in the low-SES (30.3%; 95% CI, 25.02–36.1) and medium-SES 9.6–10.2) category. Comparisons across all SES and sexual (26.4%; 95% CI, 22.3–30.9) categories than it was among orientation categories were not possible for other tobacco their counterparts in the high-SES (11.1%; 95% CI, products due to small numbers in some cells.

Table 2.15 Prevalence of ever use of cigarettes and current use of tobacco products among adults, 18 years of age and older, by socioeconomic status^a^ and sex; National Health Interview Survey (NHIS) 2019–2021, United States

Socioeconomic status and sex | Ever use of cigarettes:^c^ % (95% CI) | Current use of tobacco products:^b^ % (95% CI)
Socioeconomic status and sex | Ever use of cigarettes:^c^ % (95% CI) | Cigarettes^c^ | Cigars | Smokeless tobacco | Pipes^d^ | E-cigarettes | ≥2 tobacco products^e^
Low (< the poverty level) | 39.1 (37.7–40.6) | 22.0 (20.9–23.2) | 3.3 (2.9–3.8) | 1.9 (1.5–2.3) | 1.3 (1.0–1.6) | 4.9 (4.4–5.5) | 4.8 (4.3–5.5)
Male | 45.2 (43.0–47.5) | 25.4 (23.6–27.4) | 5.5 (4.6–6.5) | 3.6 (2.8–4.5) | 1.8 (1.3–2.4) | 5.3 (4.4–6.3) | 7.1 (6.1–8.3)
Female | 35.1 (33.3–36.8) | 19.7 (18.4–21.1) | 1.8 (1.5–2.3) | 0.8 (0.5–1.2) | 0.9 (0.7–1.3) | 4.7 (4.0–5.4) | 3.3 (2.8–3.9)
Medium (1–<2 times the poverty level) | 39.2 (38.2–40.3) | 18.1 (17.4–18.9) | 3.3 (3.0–3.7) | 2.0 (1.8–2.3) | 1.3 (1.0–1.5) | 4.8 (4.4–5.3) | 4.6 (4.2–5.0)
Male | 46.5 (44.9–48.1) | 21.2 (20.0–22.5) | 5.7 (5.0–6.4) | 4.3 (3.7–5.0) | 1.8 (1.4–2.2) | 5.6 (4.9–6.4) | 6.7 (5.9–7.5)
Female | 33.4 (32.2–34.7) | 15.6 (14.8–16.6) | 1.5 (1.2–1.8) | 0.2 (0.1–0.3) | 0.9 (0.6–1.2) | 4.1 (3.6–4.7) | 2.9 (2.5–3.3)
High (≥2 times the poverty level) | 33.9 (33.4–34.4) | 10.0 (9.7–10.3) | 3.6 (3.4–3.8) | 2.4 (2.3–2.6) | 0.9 (0.8–1.0) | 4.0 (3.8–4.2) | 3.1 (2.9–3.3)
Male | 39.1 (38.4–39.8) | 11.3 (10.9–11.8) | 6.5 (6.1–6.8) | 4.6 (4.3–4.9) | 1.3 (1.1–1.5) | 4.9 (4.6–5.3) | 4.7 (4.4–5.0)
Female | 28.6 (28.0–29.2) | 8.5 (8.2–8.9) | 0.7 (0.6–0.8) | 0.2 (0.1–0.3) | 0.5 (0.4–0.6) | 3.0 (2.8–3.3) | 1.4 (1.2–1.6)

Source: NHIS, National Center for Health Statistics, public use data, 2019–2021.

Notes:CI = confidence interval.

a Socioeconomic status was assessed by calculating the ratio of family income to the corresponding poverty threshold.

b People who currently smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes and smoking cigarettes every day or some days at the time of the survey. People who currently used other products (cigars, smokeless tobacco, pipe, e-cigarettes) was defined as those who reported having used such products every day or some days at the time of the survey.

c People who had ever used cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes.

d Pipes included use of regular pipes, water pipes, or hookah.

e Any combination of more than one tobacco product.

Table 2.16 Prevalence of ever use of cigarettes and current use of tobacco products among adults, 18 years of age and older, by socioeconomic status^a^ and race and ethnicity; National Health Interview Survey (NHIS) 2019–2021, United States

Socioeconomic status and race and ethnicity | Ever use of cigarettes:^c^ % (95% CI) | Current use of tobacco products:^b^ % (95% CI)
Socioeconomic status and race and ethnicity | Ever use of cigarettes:^c^ % (95% CI) | Cigarettes | Cigars | Smokeless tobacco | Pipes^d^ | E-cigarettes | ≥2 tobacco products^e^
Low (< the poverty level) | 39.1 (37.7–40.6) | 22.0 (20.9–23.2) | 3.3 (2.9–3.8) | 1.9 (1.5–2.3) | 1.3 (1.0–1.6) | 4.9 (4.4–5.5) | 4.8 (4.3–5.5)
American Indian and Alaska Native | 51.3 (38.5–64.0) | 23.4 (13.2–38.0) | —^f^ | —^f^ | —^f^ | —^f^ | —^f^
Asian | 18.3 (14.2–23.1) | 9.1 (6.2–13.2) | —^f^ | —^f^ | —^f^ | —^f^ | —^f^
Black | 36.7 (33.8–39.7) | 22.6 (20.1–25.3) | 5.1 (4.0–6.5) | 1.4 (0.9–2.4) | 1.2 (0.7–2.0) | 2.5 (1.6–3.6) | 3.9 (2.9–5.3)
Hispanic | 23.4 (21.2–25.8) | 11.0 (9.6–12.7) | 1.7 (1.2–2.4) | —^f^ | 1.0 (0.6–1.7) | 2.9 (2.2–3.8) | 2.2 (1.6–3.1)
Other and multiple races | 46.1 (38.2–54.3) | 30.9 (24.1–38.7) | —^f^ | —^f^ | —^f^ | —^f^ | 11.2 (6.7–18.2)
White | 53.0 (50.8–55.3) | 30.4 (28.6–32.3) | 3.9 (3.2–4.8) | 2.8 (2.2–3.6) | 1.2 (0.9–1.6) | 7.8 (6.8–9.0) | 7.0 (6.1–8.1)
Medium (1–<2 times the poverty level) | 39.2 (38.2–40.3) | 18.1 (17.4–18.9) | 3.3 (3.0–3.7) | 2.0 (1.8–2.3) | 1.3 (1.0–1.5) | 4.8 (4.4–5.3) | 4.6 (4.2–5.0)
American Indian and Alaska Native | 54.1 (40.1–67.5) | 29.9 (18.9–43.9) | —^f^ | —^f^ | —^f^ | —^f^ | —^f^
Asian | 22.3 (18.3–26.8) | 11.5 (8.6–15.3) | —^f^ | —^f^ | —^f^ | —^f^ | —^f^
Black | 30.3 (28.1–32.7) | 17.3 (15.6–19.3) | 4.6 (3.7–5.8) | —^f^ | 1.9 (1.3–2.8) | 2.0 (1.4–2.8) | 3.8 (2.9–4.9)
Hispanic | 22.3 (20.6–24.0) | 8.2 (7.2–9.4) | 2.5 (1.8–3.4) | 0.4 (0.2–0.8) | 0.6 (0.4–1.1) | 2.6 (1.9–3.4) | 1.8 (1.4–2.4)
Other and multiple races | 50.3 (43.4–57.1) | 26.3 (20.8–32.7) | 6.1 (3.5–10.4) | —^f^ | —^f^ | 13.6 (9.5–19.0) | 9.5 (6.3–14.2)
White | 52.2 (50.8–53.6) | 23.8 (22.7–24.9) | 3.4 (3.0–4.0) | 3.4 (2.9–4.0) | 1.4 (1.1–1.8) | 6.7 (6.0–7.5) | 6.3 (5.6–7.0)
High (≥2 times the poverty level) | 33.9 (33.4–34.4) | 10.0 (9.7–10.3) | 3.6 (3.4–3.8) | 2.4 (2.3–2.6) | 0.9 (0.8–1.0) | 4.0 (3.8–4.2) | 3.1 (2.9–3.3)
American Indian and Alaska Native | 39.5 (32.0–47.5) | 18.2 (12.6–25.5) | —^f^ | —^f^ | —^f^ | —^f^ | 5.9 (3.3–10.3)
Asian | 18.2 (16.7–19.7) | 5.6 (4.8–6.6) | 1.2 (0.9–1.7) | 0.6 (0.4–0.9) | 0.8 (0.5–1.2) | 3.2 (2.6–4.0) | 1.5 (1.1–2.0)
Black | 22.2 (20.9–23.7) | 9.2 (8.2–10.3) | 4.6 (3.9–5.4) | 0.5 (0.3–0.8) | 1.5 (1.2–2.0) | 2.7 (2.2–3.3) | 2.7 (2.2–3.3)
Hispanic | 23.6 (22.4–24.9) | 7.2 (6.5–8.0) | 2.9 (2.4–3.4) | 0.7 (0.5–0.9) | 0.9 (0.7–1.2) | 3.2 (2.8–3.8) | 2.4 (2.0–2.8)
Other and multiple races | 36.5 (33.0–40.1) | 13.0 (10.4–16.2) | 4.0 (2.4–6.5) | 2.3 (1.4–3.7) | —^f^ | 7.7 (5.9–10.0) | 5.8 (3.8–8.9)
White | 38.5 (38.0–39.1) | 10.8 (10.4–11.2) | 3.8 (3.6–4.0) | 3.1 (2.9–3.3) | 0.8 (0.7–0.9) | 4.3 (4.0–4.5) | 3.3 (3.1–3.5)

Source: NHIS, National Center for Health Statistics, public use data, 2019–2021.

Notes:CI = confidence interval.

a Socioeconomic status was assessed by calculating the ratio of family income to the corresponding poverty threshold.

b People who currently smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes and smoking cigarettes every day or some days at the time of the survey. People who currently used other products (cigars, smokeless tobacco, pipe, e-cigarettes) was defined as those who reported having used such products every day or some days at the time of the survey.

c People who had ever used cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes.

d Pipes included use of regular pipes, water pipes, or hookah.

e Any combination of more than one tobacco product.

f Unstable estimate is not presented because of a relative standard error >0.3 or an unweighted denominator <50.

Table 2.17 Prevalence of ever use of cigarettes and current use of tobacco products among adults, 18 years of age and older, by socioeconomic status^a^ and sexual orientation; National Health Interview Survey (NHIS) 2019–2021, United States

Socioeconomic status and sexual orientation | Ever use of cigarettes:^c^ % (95% CI) | Current use of tobacco products:^b^ % (95% CI)
Socioeconomic status and sexual orientation | Ever use of cigarettes:^c^ % (95% CI) | Cigarettes | Cigars | Smokeless tobacco | Pipes^d^ | E-cigarettes | ≥2 tobacco products^e^
Low (< the poverty level) | 39.1 (37.7–40.6) | 22.0 (20.9–23.2) | 3.3 (2.9–3.8) | 1.9 (1.5–2.3) | 1.3 (1.0–1.6) | 4.9 (4.4–5.5) | 4.8 (4.3–5.5)
Heterosexual | 39.0 (37.5–40.5) | 21.6 (20.4–22.8) | 3.2 (2.7–3.7) | 1.9 (1.6–2.4) | 1.2 (0.9–1.5) | 4.5 (4.0–5.1) | 4.5 (4.0–5.2)
Not heterosexual (all)^f^ | 44.4 (38.3–50.7) | 30.3 (25.0–36.1) | 5.9 (3.7–9.2) | —^g^ | 3.8 (2.2–6.7) | 13.9 (10.2–18.8) | 11.8 (8.5–16.3)
Gay | 34.9 (21.5–51.2) | 31.2 (18.6–47.3) | —^g^ | —^g^ | —^g^ | —^g^ | —^g^
Lesbian | 55.8 (40.6–70.1) | 33.5 (20.1–50.2) | —^g^ | —^g^ | —^g^ | —^g^ | —^g^
Bisexual | 44.8 (36.4–53.5) | 30.5 (23.6–38.3) | 7.8 (4.6–13.0) | —^g^ | —^g^ | 17.8 (12.3–25.1) | 13.7 (9.0–20.3)
Medium (1–<2 times the poverty level) | 39.2 (38.2–40.3) | 18.1 (17.4–18.9) | 3.3 (3.0–3.7) | 2.0 (1.8–2.3) | 1.3 (1.0–1.5) | 4.8 (4.4–5.3) | 4.6 (4.2–5.0)
Heterosexual | 39.3 (38.3–40.4) | 17.9 (17.1–18.7) | 3.2 (2.8–3.6) | 2.1 (1.8–2.4) | 1.3 (1.0–1.5) | 4.3 (3.9–4.8) | 4.3 (3.9–4.7)
Not heterosexual (all) | 44.0 (39.1–49.0) | 26.4 (22.3–30.9) | 6.8 (4.7–9.8) | —^g^ | —^g^ | 17.3 (13.6–21.6) | 11.6 (8.8–15.1)
Gay | 47.4 (35.7–59.5) | 25.7 (17.0–36.9) | —^g^ | N/A | N/A | —^g^ | —^g^
Lesbian | 33.9 (23.8–45.7) | 19.2 (11.8–29.8) | —^g^ | N/A | —^g^ | —^g^ | —^g^
Bisexual | 49.6 (42.7–56.5) | 31.6 (25.6–38.3) | 9.5 (6.0–14.5) | —^g^ | —^g^ | 23.6 (17.9–30.3) | 16.2 (11.7–21.9)
High (≥2 times the poverty level) | 33.9 (33.4–34.4) | 10.0 (9.7–10.3) | 3.6 (3.4–3.8) | 2.4 (2.3–2.6) | 0.9 (0.8–1.0) | 4.0 (3.8–4.2) | 3.1 (2.9–3.3)
Heterosexual | 33.9 (33.4–34.4) | 9.9 (9.6–10.2) | 3.6 (3.4–3.8) | 2.5 (2.3–2.7) | 0.8 (0.8–0.9) | 3.8 (3.6–4.0) | 3.0 (2.8–3.2)
Not heterosexual (all) | 35.3 (33.0–37.6) | 11.1 (9.6–12.8) | 3.3 (2.4–4.7) | 0.9 (0.6–1.4) | 2.2 (1.4–3.2) | 9.1 (7.7–10.8) | 4.2 (3.2–5.6)
Gay | 40.0 (35.8–44.5) | 13.7 (10.5–17.7) | —^g^ | —^g^ | —^g^ | 7.0 (5.2–9.4) | 5.9 (3.5–9.9)
Lesbian | 31.2 (26.8–36.1) | 9.1 (6.7–12.4) | —^g^ | —^g^ | —^g^ | 5.1 (3.0–8.4) | —^f^
Bisexual | 34.7 (30.9–38.7) | 9.9 (7.6–12.7) | 3.3 (2.1–5.3) | —^g^ | 2.5 (1.5–4.1) | 11.8 (9.3–14.8) | 4.1 (2.8–6.0)

Source: NHIS, National Center for Health Statistics, public use data, 2019–2021.

Notes:CI = confidence interval; N/A = not available.

a Socioeconomic status was assessed by calculating the ratio of family income to the corresponding poverty threshold.

b People who currently smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes and smoking cigarettes every day or some days at the time of the survey. People who currently used other products (cigars, smokeless tobacco, pipe, e-cigarettes) was defined as those who reported having used such products every day or some days at the time of the survey.

c People who had ever used cigarettes was defined as those who reported having smoked at least 100 cigarettes in their lifetimes.

d Pipes included use of regular pipes, water pipes, or hookah.

e Any combination of more than one tobacco product.

f Includes people who identified as gay, lesbian, or bisexual or who reported “something else.”

g Unstable estimate is not presented because of a relative standard error >0.3 or an unweighted denominator <50.

## Tobacco Use Among Occupational Groups

This section describes disparities by occupational class, occupational profession and industry, and employment status across the spectrum of tobacco products to characterize current use and cessation. To the extent possible, information is included on the intersections between occupation and employment status and other population characteristics, such as sex, age, race and ethnicity, and sexual orientation. Although most of the relevant research focuses on cigarette use, research on the use of other tobacco products is included if available.

Consistent with previous reports (e.g., NCI 2017), occupational class generally refers to manual labor, service, or white-collar jobs.^2^ Occupational profession and industry represents a breakdown of occupational class by profession and industry, which may vary among studies. Examples of professions may include construction workers, laborers, fabricators, food service personnel, health-diagnosing occupations, and teachers. Examples of industries may include construction, food service, retail trade, mining, finance, and educational services. Finally, employment status describes the participation of people in the labor force.

Data from the 1995–2018 TUS-CPS among adults (18 years of age and older) indicate that trends for ever smoking and current daily smoking were consistent for occupational categories, with the construction and manual labor or service sector industries having the highest rates for both smoking statuses (Figure 2.8, Parts A and B).^3^ Trends for persistent smoking (defined as current daily smoking among those who reported ever smoking) were distinctly lower among white-collar workers than they were for the cluster of all other employment categories (Figure 2.8, Part C).

Studies reviewed by NCI in Tobacco Control Monograph 22 (2017) found that people working in manual labor and service jobs had significantly higher odds of current cigarette use than did white-collar workers (Table 2.18).^4^ The literature is less consistent about differences in smoking cessation by occupation. The existing studies suggest that white-collar workers have somewhat higher odds of quitting successfully than manual labor or service workers (Table 2.18).

### Patterns of Tobacco Use by Occupational Profession and Industry

The NHIS collects information on occupation and recodes responses to align with the U.S. Standard Occupational Classification System (U.S. Bureau of Labor Statistics n.d.). Based on data from the 2020–2021 NHIS on employment characteristics and use of tobacco products among an estimated 150 million working adults, 19.3% (95% CI, 18.7–19.9) currently used a tobacco product (Table 2.19). By product, estimates of current use among working adults were 11.4% (95% CI, 10.9–11.8) for cigarettes, 4.8% (95% CI, 4.5–5.1) for other combustible tobacco products, 1.7% (95% CI, 1.5–1.9) for smokeless tobacco, and 4.9% (95% CI, 4.6–5.2) for e-cigarettes (Table 2.19). Overall, 3.1% (95% CI, 2.8–3.3) of working adults used two or more tobacco products.

Table 2.20 presents the prevalence of current tobacco use among U.S. working adults by profession and industry. The highest prevalence of current tobacco use was among workers in construction (31.1%; 95% CI, 28.6–33.5), followed by workers in utilities (27.4%; 95% CI, 20.5–34.3); manufacturing (25.5%; 95% CI, 23.6–27.4); accommodation and food services (25.0%; 95% CI, 22.3–27.6); agriculture, forestry, fishing, and hunting (24.9%; 95% CI, 20.0–29.7); administrative and support and waste management and remediation services (24.8%; 95% CI, 22.1–27.5); and transportation and warehousing (24.3%; 95% CI, 21.6–27.5). The lowest prevalence of any tobacco use was among workers in education services (9.1%; 95% CI, 8.0–10.3).

Figure 2.8 Percentage of ever smoking, current daily smoking, and persistent smoking over time, by occupational category; Tobacco Use Supplement to the Current Population Survey (TUS-CPS) 1995–2018,^a^ a TUS-CPS is administered approximately every 3–4 years, not annually. In this figure, data collected in 1995–1996 are presented as “1995”; 1998–1999 are presented as “1998”; 2001–2002 are presented as “2001”; 2006–2007 are presented as “2006”; 2010–2011 are presented as “2010”; 2014–2015 are presented as “2014”; and 2018–2019 are presented as “2018.” United States

Notes: Figure is based on data presented in Figure 1 of Ham and colleagues (2011). As such, the terminology used to describe each occupational category is consistent with that study. However, analyses have been completed using the Harmonized TUS-CPS dataset, so some of the results present differently from those in Ham and colleagues (2011).

^b^The construction industry is a subset of blue collar occupations, so data from the construction industry are also included in blue collar category; however, construction-specific estimates are also provided. The construction occupational category from 1995 to 2002 contained handlers, equipment cleaners, helpers, laborers and a subset of precision production, craft and repair occupations titled, “construction trade.” But due to changes to the Occupational Code starting in 2003, the construction occupational category includes only construction and extraction occupations (Ham et al. 2011).

A Ever smoking

The prevalence of ever smoking decreased consistently from 1995 to 2018 among people in each of the four occupational categories: “white collar,” service, “blue collar,” and construction. The prevalence of ever smoking was consistently higher among people in construction and “blue collar” jobs than it was among people in “white collar” and service jobs. Figure note “b” offers more details about the definition of the construction industry category.

B Current daily smoking

The prevalence of current daily smoking decreased consistently from 1995 to 2018 among people in each of the four occupational categories: “white collar,” service, “blue collar,” and construction. The prevalence of current daily smoking was consistently higher among people in construction and “blue collar” jobs than it was among people in “white collar” and service jobs. Figure note “b” offers more details about the definition of the construction industry category.

C Persistent smoking^c^ c Persistent smoking is defined as current daily smoking among those who reported ever smoking.

The prevalence of persistent smoking, defined as current daily smoking among those who reported ever smoking, decreased consistently from 1995 to 2018 among people in each of the four occupational categories-“white collar,” service, “blue collar,” and construction-except for a half-percentage-point increase from 1998 to 2001 among those in the construction industry. The prevalence of persistent smoking was consistently lower among people in “white color” jobs than it was among people in construction, service, and “blue collar” jobs, for which trends were similar over time. Figure note “b” offers more details about the definition of the construction industry category.

Source: Harmonized TUS-CPS, National Cancer Institute, public use data, 1995–2018.

#### Cigarettes

The highest prevalence of current cigarette smoking by industry was among workers in construction (20.2%; 95% CI, 18.0–22.4), followed by workers in manufacturing (16.4%; 95% CI, 14.8–18.0), utility workers (15.8%; 95% CI, 9.5–22.0), accommodation and food services workers (15.6%; 95% CI, 13.6–17.7), and administrative and support and waste management and remediation services workers (15.2%; 95% CI, 13.0–17.5). The lowest prevalence of smoking by industry was among workers in education services (4.1%; 95% CI, 3.3–4.9) (Table 2.20).

#### E-Cigarettes

The highest prevalence of current e-cigarette use by industry was among workers in accommodation and food services (9.0%; 95% CI, 7.1–10.9), followed by workers in retail trade (7.3%; 95% CI, 6.0–8.5), information workers (7.2%; 95% CI, 4.7–9.7), and transportation and warehousing workers (6.1%; 95% CI, 4.5–7.7). The lowest prevalence of e-cigarette use by industry was among workers in education services (2.2%; 95% CI, 1.6–2.8) (Table 2.20).

Table 2.18 Cigarette use across the tobacco use continuum, per nationally representative data, by occupational class

Continuum phase and author(s) | Data source and year, sample size, and age range | Prevalence (%) | | | | Odds ratio/relative risk (95% CI)
Continuum phase and author(s) | Data source and year, sample size, and age range | White collar | Blue collar | Service | Other | White collar | Blue collar | Service | Other
Current use (prevalence of cigarette smoking)
Barbeau et al. (2004) | - NHIS 2000; - n = 24,276; - 18–64 years of age; - Adjusted for age, gender, race and ethnicity | 20.3 | 35.4 | 31.1 | 24.2^a^ | aOR = 1.00 | aOR = 1.28 (1.15–1.41) | aOR = 1.19 (1.05–1.36) | aOR = 0.72 (0.55–0.94)
Fagan et al. (2007) | - TUS-CPS 1998–1999, 2001–2002; - n = 288,813; - 18–64 years of age; - Adjusted for age, gender, marital status, level of educational attainment, family income, race and ethnicity, occupation, hours per week, number of jobs, self-employment | 18 | 33 | 27 | 24^a,b^ | aOR = 1.00 | aOR = 1.31 (1.27–1.35) | aOR = 1.15 (1.10–1.20) | —^c^
Lawrence et al. (2007) | - TUS-CPS 1998–1999; - n = 15,394; - 18–24 years of age; - Adjusted for gender, race and ethnicity, employment status, occupation, geographic region, income, metropolitan status, school enrollment | 22.6 | 34.5 | 31.6 | 20.5^d^ | aOR = 1.00 | aOR = 1.50 (1.32–1.70) | aOR = 1.62 (1.42–1.84) | aOR = 1.11 (0.88–1.41)
Ham et al. (2011) | - TUS-CPS 2006–2007; - n = 106,604; - 18–64 years of age; - Adjusted for all demographic categories | 11.7 | 24.0 | 19.7 | 25.6^e^ | aRR = 1.00 | aRR = 1.41 (1.34–1.49) | aRR = 1.25 (1.18–1.32) | —^c^
Asfar et al. (2016) | - NHIS 2010; - n = 1,531; - 18–24 years of age; - Adjusted for survey year, occupational group, age, gender, race and ethnicity, level of educational attainment, income, health insurance status | 18.2 | 24.9 | 24.2 | —^c^ | aOR = 1.00 | aOR = 1.40 (1.01–1.93) | aOR = 1.36 (1.02–1.98) | —^c^
Past-year quit attempt (stopped smoking for 1 or more days during past 12 months)
Barbeau et al. (2004) | - NHIS 2000; - n = 24,276; - 18–64 years of age | 44.8 | 42.1 | 46.7 | 42.4 | —^c^ | —^c^ | —^c^ | —^c^
Alexander et al. (2010) | - TUS-CPS 2006–2007; - n = 30,176; - 18 years of age and older | 51.6 | 50.8 | 55.5 | —^c^ | OR = 1.00 | OR = 0.87 (0.73–1.10) | OR = 0.80 (0.69–0.94) | —^c^
Ham et al. (2011) | - TUS-CPS 2006–2007; - n = 106,604; - 18–64 years of age; - Adjusted for all demographic categories | 46.0 | 38.6 | 41.7 | 37.6^e^ | aRR = 1.00 | aRR = 0.94 (0.88–1.01) | aRR = 0.99 (0.92–1.06) | —^c^
Asfar et al. (2016) | - NHIS 2010; - n = 1,531; - 18–24 years of age; - Adjusted for survey year, occupational group, age, gender, race and ethnicity, level of educational attainment, income, health insurance status | 57.8 | 57.9 | 53.9 | —^c^ | aOR = 1.00 | aOR = 0.70 (0.46–1.06) | aOR = 0.85 (0.51–1.40) | —^c^
Barbeau et al. (2004) | - NHIS 2000; - n = 24,276; - 18–64 years of age | 20.4 | 18.0 | 14.4 | 16.6^a^ | —^c^ | —^c^ | —^c^ | —^c^
Fagan et al. (2007) | - TUS-CPS 1998–1999, 2001–2002; - n = 288,813; - 18–64 years of age; - Adjusted for age, gender, marital status, level of educational attainment, family income, occupation, hours per week, self-employment, age of onset, everyday smoking for 6 months | 19 | 18 | 14 | 16^a,b^ | aOR = 1.00 | aOR = 0.80 (0.76–0.83) | aOR = 0.81 (0.77–0.85) | —^c^
Relapse
None | | —^c^ | —^c^ | —^c^ | —^c^ | —^c^ | —^c^ | —^c^ | —^c^

Source: National Cancer Institute (2017, pp. 275–276).

Notes:aOR = adjusted odds ratio; aRR = adjusted relative risk; CI = confidence interval; NHIS = National Health Interview Survey; OR = odds ratio; TUS-CPS = Tobacco Use Supplement to the Current Population Survey.

a Other industry was farming.

b Other industry was forestry and fishing.

c Not applicable or insufficient data.

d Unknown or refused to answer.

e Other industry was construction.

Table 2.19 Estimated prevalence of current use of tobacco products among working adults,^a^ by product type and selected demographic characteristics; National Health Interview Survey (NHIS) 2020–2021, United States

Characteristics | Number of currently employed adults:^b^ (x1,000) | Cigarettes:^c^ % (95% CI) | Other combustible tobacco products:^d^ % (95% CI) | Smokeless tobacco products:^e^ % (95% CI) | E-cigarettes:^f^ % (95% CI) | Any tobacco product:^g^ % (95% CI) | ≥2 tobacco products:^h^ % (95% CI)
Total (100%) | 150,981 | 11.4 (10.9–11.8) | 4.8 (4.5–5.1) | 1.7 (1.5–1.9) | 4.9 (4.6–5.2) | 19.3 (18.7–19.9) | 3.1 (2.8–3.3)
Age group (years)
≥18–34 | 52,802 | 9.1 (8.4–9.8) | 6.3 (5.7–7.0) | 1.4 (1.1–1.7) | 8.7 (8.0–9.4) | 20.6 (19.5–21.6) | 4.4 (3.9–4.9)
≥35–54 | 62,417 | 13.2 (12.5–13.8) | 4.5 (4.1–5.0) | 2.1 (1.8–2.4) | 3.6 (3.2–4.0) | 20.2 (19.4–21.0) | 2.9 (2.6–3.2)
≥55 | 35,762 | 11.3 (10.5–12.0) | 3.0 (2.7–3.4) | 1.3 (1.1–1.6) | 1.6 (1.3–1.9) | 15.7 (14.8–16.5) | 1.5 (1.2–1.7)
Sex
Male | 79,823 | 12.8 (12.2–13.5) | 7.5 (7.0–8.0) | 3.1 (2.8–3.5) | 5.6 (5.2–6.0) | 24.2 (23.4–25.1) | 4.3 (3.9–4.7)
Female | 71,132 | 9.5 (8.9–10.1) | 1.8 (1.5–2.1) | 0.1 (0.0–0.1) | 4.1 (3.7–4.5) | 13.7 (13.0–14.4) | 1.7 (1.4–1.9)
Race and ethnicity
Black, non-Hispanic | 16,485 | 10.3 (9.0–11.7) | 7.3 (6.1–8.5) | —^i^ | 2.4 (1.8–3.0) | 17.1 (15.4–18.8) | 2.9 (2.2–3.5)
Hispanic | 26,954 | 8.3 (7.3–9.3) | 3.6 (3.0–4.2) | 0.3 (0.1–0.5) | 3.6 (3.0–4.2) | 13.2 (12.0–14.3) | 2.3 (1.8–2.7)
White, non-Hispanic | 94,389 | 12.7 (12.1–13.2) | 5.0 (4.6–5.3) | 2.5 (2.2–2.8) | 5.7 (5.2–6.1) | 22.0 (21.3–22.8) | 3.4 (3.1–3.7)
Other | 13,154 | 8.7 (7.4–10.4) | 3.0 (2.3–3.7) | 0.6 (0.3–0.9) | 5.3 (4.3–6.3) | 14.7 (13.0–16.3) | 2.7 (2.0–3.5)
Education
< High school | 5,015 | 22.4 (19.2–25.6) | 4.3 (2.8–5.8) | —^i^ | 3.5 (2.1–4.9) | 26.3 (22.8–29.8) | 4.4 (2.8–6.1)
High School/GED | 25,574 | 20.1 (18.8–21.4) | 4.9 (4.2–5.5) | 2.4 (1.9–2.9) | 6.6 (4.3–4.9) | 28.8 (27.3–30.2) | 4.7 (4.0–5.4)
> High school | 120,002 | 8.9 (8.5–9.4) | 4.8 (4.5–5.2) | 1.5 (1.3–1.7) | 4.6 (4.3–4.9) | 16.9 (16.3–17.5) | 2.7 (2.4–2.9)
Unknown | 391 | —^i^ | —^i^ | —^i^ | —^i^ | 25.2 (12.6–45.8) | —^i^
Poverty index^j^
Poor | 9,018 | 18.3 (16.2–20.4) | 4.6 (3.4–5.8) | 0.6 (0.2–1.0) | 5.2 (4.0–6.5) | 24.3 (21.9–26.7) | 3.9 (2.8–5.0)
Near poor | 21,385 | 17.3 (16.0–18.7) | 4.9 (4.1–5.7) | 1.3 (0.9–1.6) | 6.8 (5.7–7.8) | 25.0 (23.5–26.6) | 4.7 (4.0–5.5)
Not poor | 110,604 | 9.4 (9.0–9.9) | 4.8 (4.5–5.2) | 1.8 (1.6–2.0) | 4.4 (4.1–4.8) | 17.6 (16.9–18.2) | 2.7 (2.4–2.9)
Unknown | 9,973 | —^i^ | —^i^ | —^i^ | —^i^ | —^i^ | —^i^
Health insurance
Not insured | 17,147 | 21.0 (19.3–22.7) | 6.1 (5.1–7.1) | 1.8 (1.3–2.4) | 6.3 (5.2–7.4) | 28.8 (26.8–30.7) | 5.9 (4.9–6.8)
Insured | 133,390 | 10.0 (9.6–10.5) | 4.6 (4.3–4.9) | 1.7 (1.5–1.9) | 4.7 (4.4–5.0) | 18.0 (17.5–18.6) | 2.7 (2.5–2.9)
Unknown | 445 | —^i^ | —^i^ | —^i^ | —^i^ | —^i^ | —^i^
U.S. Census region^k^
Northeast | 26,519 | 9.4 (8.4–10.4) | 4.3 (3.6–5.1) | 0.9 (0.6–1.2) | 3.5 (2.8–4.1) | 16.1 (14.7–17.6) | 1.8 (1.4–2.3)
Midwest | 32,821 | 14.1 (13.1–15.2) | 5.1 (4.4–5.8) | 2.5 (2.0–2.9) | 5.2 (4.5–5.9) | 22.8 (21.5–24.1) | 3.7 (3.1–4.3)
South | 55,189 | 12.4 (11.6–13.2) | 5.4 (4.9–5.9) | 1.9 (1.6–2.3) | 5.0 (4.5–5.6) | 20.8 (19.8–21.9) | 3.6 (3.2–4.0)
West | 36,451 | 8.4 (7.6–9.1) | 4.0 (3.4–4.5) | 1.2 (0.9–1.4) | 5.5 (4.9–6.1) | 16.0 (15.1–16.9) | 2.7 (2.2–3.1)

Source: NHIS, National Center for Health Statistics, public use data, 2020–2021.

Notes:CI = confidence interval; GED = General Educational Development certificate or diploma.

a Adults who reported “working at a job or business,” “with a job or business but not at work,” or “working, but not for pay, at a family-owned job or business” during the week before the interview.

b Weighted to provide national annual average estimates for current employment.

c People who currently smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes during their lifetimes and who currently smoked every day or some days (estimated n = 17.0 million).

d People who used other combustible tobacco products was defined as those who reported having smoked cigars, cigarillos, or little filtered cigars or smoking tobacco in a regular pipe, water pipe, or hookah at least once during their lifetimes and who currently use such a product every day or some days (estimated n = 7.3 million).

e People who used smokeless tobacco products was defined as those who reported having used chewing tobacco, snuff, dip, snus, or dissolvable tobacco at least once during their lifetimes and who currently use such a product every day or some days (estimated n = 2.5 million).

f People who used e-cigarettes was defined as those who reported having used e-cigarettes at least once during their lifetimes and who currently used e-cigarettes every day or some days (n = 7.4 million).

g People who used any tobacco product was defined as those who reported currently using cigarettes or other combustible tobacco or smokeless tobacco or e-cigarettes every day or some days (estimated n = 29.0 million).

h People who used two or more tobacco products was defined as those who reported currently using two or more tobacco products (estimated n = 4.6 million).

i Estimate suppressed (relative standard error >30%).

j Poverty status was based on family income and family size using the U.S. Census Bureau’s poverty thresholds for the previous calendar year. In the NHIS, poor was defined as having incomes below the poverty threshold; near poor was defined as having incomes of 100% to less than 200% of the poverty threshold; and not poor was defined as having incomes that are 200% or more of the poverty threshold. Additional information is available at National Center for Health Statistics (2016).

k U.S. Census Bureau (n.d.a).

Table 2.20 Prevalence of current use of tobacco products among U.S. working adults,^a^ 18 years of age and older, by type of tobacco product and industry sector; National Health Interview Survey (NHIS) 2020–2021, United States

Industry sector | Number of currently working adults^b^ (in 1,000s) | Cigarettes:^c^ % (95% CI) | Other combustible tobacco products:^d^ % (95% CI) | Smokeless tobacco:^e^ % (95% CI) | E cigarettes:^f^ % (95% CI) | Any tobacco product:^g^ % (95% CI) | Two or more tobacco products:^h^ % (95% CI)
Construction | 11,460 | 20.2 (18.0–22.4) | 6.5 (5.3–7.7) | 5.1 (4.0–6.3) | 5.2 (4.0–6.3) | 31.1 (28.6–33.5) | 5.4 (4.3–6.6)
Manufacturing | 14,252 | 16.4 (14.8–18.0) | 5.6 (4.6–6.5) | 3.1 (2.3–4.0) | 5.4 (4.4–6.4) | 25.5 (23.6–27.4) | 4.4 (3.5–5.2)
Utilities | 1,346 | 15.8 (9.5–22.0) | 5.7 (2.6–8.9) | 5.3 (2.4–8.2) | —^i^ | 27.4 (20.5–34.3) | —^i^
Accommodation & food services | 8,232 | 15.6 (13.6–17.7) | 4.2 (2.8–5.5) | —^i^ | 9.0 (7.1–10.9) | 25.0 (22.3–27.6) | 3.9 (2.6–5.1)
Administrative & support & waste management & remediation services | 6,997 | 15.2 (13.0–17.5) | 6.3 (4.8–7.9) | 2.0 (1.2–2.9) | 6.0 (4.5–7.5) | 24.8 (22.1–27.5) | 4.2 (3.0–5.5)
Agriculture, forestry, fishing & hunting | 1,971 | 13.9 (9.4–18.3) | 3.3 (1.4–5.2) | 6.9 (4.2–9.6) | 4.6 (2.3–6.9) | 24.9 (20.0–29.7) | 3.8 (1.8–5.8)
Transportation & warehousing | 7,509 | 13.7 (11.5–16.0) | 6.8 (5.1–8.4) | 2.2 (1.2–3.1) | 6.1 (4.5–7.7) | 24.3 (21.6–27.1) | 4.0 (2.8–5.2)
Retail trade | 14,317 | 12.9 (11.5–14.3) | 4.3 (3.5–5.1) | 0.9 (0.6–1.3) | 7.3 (6.0–8.5) | 21.4 (19.6–23.1) | 3.8 (2.9–4.6)
Other services (except public administration) | 7,890 | 11.4 (9.6–13.2) | 5.0 (3.8–6.2) | 1.8 (1.0–2.6) | 4.8 (3.5–6.1) | 19.7 (17.3–22.0) | 3.0 (2.1–3.9)
Arts, entertainment, & recreation | 2,648 | 11.3 (8.4–14.3) | 6.0 (3.7–8.4) | —^i^ | 4.5 (2.5–6.5) | 17.4 (13.9–20.9) | 3.8 (1.9–5.7)
Information | 2,984 | 10.3 (7.6–13.0) | 7.2 (4.8–9.6) | —^i^ | 7.2 (4.7–9.7) | 21.4 (17.8–25.0) | 3.3 (1.7–4.9)
Wholesale trade | 3,121 | 10.0 (7.3–12.8) | 7.8 (5.3–10.3) | —^i^ | 6.0 (3.9–8.2) | 21.9 (18.3–25.5) | 3.0 (1.3–4.6)
Real estate & rental & leasing | 2,782 | 9.6 (7.1–12.1) | 5.7 (3.7–7.7) | —^i^ | 5.2 (3.1–7.4) | 18.6 (15.3–21.9) | 3.5 (1.8–5.1)
Healthcare & social assistance | 20,646 | 8.8 (7.8–9.8) | 2.6 (2.0–3.2) | 0.3 (0.1–0.5) | 3.6 (2.9–4.3) | 13.4 (12.2–14.6) | 1.7 (1.3–2.2)
Public administration | 7,622 | 8.5 (7.1–9.8) | 5.4 (4.2–6.7) | 1.7 (1.0–2.4) | 3.2 (2.2–4.1) | 15.9 (14.1–17.7) | 2.8 (1.8–3.7)
Professional, scientific, & technical services | 12,704 | 5.9 (5.0–6.8) | 5.7 (4.6–6.7) | 0.7 (0.4–1.1) | 3.8 (3.0–4.6) | 13.6 (12.2–15.0) | 2.3 (1.7–3.0)
Finance & insurance | 7,384 | 5.8 (4.6–7.0) | 4.5 (3.3–5.6) | —^i^ | 4.1 (3.0–5.2) | 14.0 (12.1–15.9) | 1.4 (0.8–2.1)
Education services | 13,165 | 4.1 (3.3–4.9) | 2.7 (2.0–3.4) | 0.9 (0.5–1.4) | 2.2 (1.6–2.8) | 9.1 (8.0–10.3) | 0.8 (0.4–1.1)
Mining | 506 | —^i^ | —^i^ | —^i^ | —^i^ | 16.8 (9.4–24.2) | —^i^
Management of companies & enterprises | 158 | —^i^ | —^i^ | —^i^ | —^i^ | —^i^ | —^i^
Armed Forces | 89 | —^i^ | —^i^ | —^i^ | —^i^ | —^i^ | —^i^
Total | 150,981 | 11.4 (10.9–11.8) | 4.8 (4.5–5.1) | 1.7 (1.5–1.9) | 4.9 (4.6–5.2) | 19.3 (18.7–19.9) | 3.1 (2.8–3.3)

Source: NHIS, National Center for Health Statistics, public use data, 2020–2021.

Notes: An estimated 3,200 workers with unknown/unascertained/missing industry information were included in the overall (total) estimate. The 2021 NHIS public use data are the most recent to report industry/occupation information. This information was not included in the 2019 NHIS public use data. CI = confidence interval.

a Adults who reported “working at a job or business,” “with a job or business but not at work,” or “working but not for pay at a family-owned job or business” during the week before the interview.

b Weighted to provide national annual average estimates for current employment.

c People who currently smoked cigarettes was defined as those who reported having smoked at least 100 cigarettes during their lifetimes and currently smoked every day or some days (estimated N = 17.0 million).

d People who used other combustible tobacco products was defined as those who reported having smoked cigars, cigarillos, or little filtered cigars or smoking tobacco in a regular pipe, water pipe, or hookah at least once during their lifetimes and currently using such a product every day or some days (estimated N = 7.3 million).

e People who used smokeless tobacco was defined as those who reported having used chewing tobacco, snuff, dip, snus, or dissolvable tobacco at least once during their lifetimes and currently using such a product every day or some days (estimated N = 2.5 million).

f People who used e-cigarettes was defined as those who reported having used e-cigarettes at least once during their lifetimes and currently using them every day or some days (N = 7.4 million).

g People who used any tobacco product was defined as those who reported currently using cigarettes or other combustible tobacco or smokeless tobacco products or e-cigarettes every day or some days (estimated N = 29.0 million).

h People who used two or more tobacco products was defined as those who reported currently using two or more tobacco products (estimated N = 4.6 million).

i Estimate suppressed (relative standard error >30%).

#### Smokeless Tobacco

The highest prevalence of current smokeless tobacco use by industry was among workers in agriculture, forestry, fishing, and hunting (6.9%; 95% CI, 4.2–9.6), followed by utility workers (5.3%; 95% CI, 2.4–8.2) and construction workers (5.1%; 95% CI, 4.0–6.3). The lowest prevalence of smokeless tobacco use by industry was among workers in healthcare and social assistance (0.3%; 95% CI, 0.1–0.5) (Table 2.20).

#### Other Combustible Tobacco Products

The highest prevalence of current use of other combustible tobacco products (including cigars, cigarillos, or little filtered cigars or smoking tobacco in a regular pipe, water pipe, or hookah) by industry was among workers in wholesale trade (7.8%; 95% CI, 5.3–10.3), followed by information workers (7.2%; 95% CI, 4.8–9.6) and workers in transportation and warehousing (6.8%; 95% CI, 5.1–8.4). The lowest prevalence of use of other combustible tobacco products by industry was among workers in healthcare and social assistance (2.6%; 95% CI, 2.0–3.2) (Table 2.20).

### Patterns of Polytobacco Use by Occupational Profession and Industry

Backinger and colleagues (2008) reviewed several years of data (1995–1996, 1998, 2000, and 2001–2002) from the TUS-CPS to examine the use of cigarettes and at least one other tobacco product (concurrent use) by occupational status. These authors found that the prevalence of concurrent use was generally higher among manual labor or service workers (6.5–12.2%) than among workers in other occupational groups; categories were based on the Standard Occupational Classification System. In multivariable analyses, occupation was not a significant predictor of concurrent tobacco use among workers who smoked cigarettes currently and daily, but manual labor or service workers who smoked intermittently had 22% higher odds of any other tobacco use compared with white-collar workers.

NHIS data from 2020 to 2021 show that the prevalence of multiple tobacco product use was highest among people employed in construction (5.4%; 95% CI, 4.3–6.6), followed by those in manufacturing (4.4%; 95% CI, 3.5–5.5) and administrative and support and waste management and remediation services (4.2%; 95% CI, 3.0–5.5). The lowest prevalence of multiple tobacco product use by industry was among workers in education services (0.8%; 95% CI, 0.4–1.1) (Table 2.20).

### Patterns of Smoking Cessation by Sex and by Occupational Profession and Industry

Table 2.21 shows data from the 2018–2019 TUS-CPS on past-year quit attempts and cessation of 6 months or longer by occupational category, tobacco product, and sex. Past-year quit attempts in men ranged from 33.9% (95% CI, 30.0–37.7) (manual labor, smokeless) to 52.4% (95% CI, 50.1–54.6) (white collar, cigarettes). Past-year quit attempts among women ranged from 37.1% (95% CI, 20.8–53.4) (manual labor, cigars) to 56.7% (95% CI, 50.4–63.0) (white collar, cigars). Prevalence of sustained cessation for 6 or more months among men ranged from 6.4% (95% CI, 5.4–7.4) (manual labor, cigarettes) to 28.4% (95% CI, 20.6–36.2) (service, cigars). Prevalence of sustained cessation for 6 or more months among women ranged from 4.8% (95% CI, 2.7–7.0) (manual labor, cigarettes) to 37.8% (95% CI, 31.4–44.2) (white collar, cigars). Sustained cessation differed by product, with cigarettes having the lowest rates of sustained cessation across occupational category and sex compared with other products.

## Tobacco Use by Disability Status

People with disabilities comprise about one-quarter of the adult population (Okoro et al. 2018), but few studies have addressed the prevalence of tobacco use in this group. Data from the 2020 NHIS indicate that, compared with adults who report not having a disability, adults with disabilities reported a higher prevalence of current cigarette use (disability: 19.8%; 95% CI, 17.8–22.0 vs. no disability: 11.8%; 95% CI, 11.2–12.3), any tobacco product use (disability: 25.4%; 95% CI, 23.3–27.6 vs. no disability: 18.4%; 95% CI, 17.8–19.4), any combustible tobacco product use (disability: 21.6%; 95% CI, 19.6–23.8 vs. no disability: 14.6%; 14.0–15.2), and use of multiple tobacco products (disability: 4.8%; 95% CI, 3.6–6.1 vs. no disability: 3.2%; 95% CI, 2.8–3.5). The prevalence of use of other tobacco products (e.g., e-cigarettes, pipes, cigars, and smokeless tobacco) was similar for people with and without disabilities (Cornelius et al. 2022).

Table 2.21 Prevalence of a past-year quit attempt^a^ and a sustained quit for 6 or more months,^b^ by occupational category,^c^ type of tobacco product, and sex; Tobacco Use Supplement to the Current Population Survey (TUS-CPS) 2018–2019, United States

Type of tobacco product | White collar: % (95% CI) | | Manual labor: % (95% CI) | | Service: % (95% CI) | | Other: % (95% CI)
Type of tobacco product | Men | Women | Men | Women | Men | Women | Men | Women
Cigarettes
Past-year quit attempt | 52.4 (50.1–54.6) | 53.6 (51.3–55.8) | 46.3 (44.0–48.6) | 53.1 (48.0–58.1) | 50.8 (47.3–54.3) | 55.6 (52.5–58.7) | 49.6 (33.2–66.0) | —^d^
Sustained quit ≥6 months | 10.1 (8.7–11.5) | 8.2 (7.0–9.5) | 6.4 (5.4–7.4) | 4.8 (2.6–7.0) | 7.0 (5.1–8.8) | 8.2 (6.1–10.2) | —^d^ | —^d^
Cigars
Past-year quit attempt | 41.9 (38.8–45.0) | 56.7 (50.4–63.0) | 41.4 (36.7–46.0) | 37.1 (20.8–53.4) | 43.7 (36.4–51.1) | 54.1 (43.1–65.0) | —^d^ | —^d^
Sustained quit ≥6 months | 25.5 (22.9–28.1) | 37.8 (31.4–44.2) | 26.4 (22.8–30.0) | 14.3 (1.2–27.3) | 28.4 (20.6–36.2) | 36.0 (25.9–46.1) | —^d^ | —^d^
E-cigarettes
Past-year quit attempt | 47.1 (43.3–50.9) | 48.2 (45.0–51.5) | 48.4 (43.7–53.0) | 47.5 (37.8–57.2) | 48.0 (40.7–55.4) | 53.0 (46.4–59.7) | —^d^ | —^d^
Sustained quit ≥6 months | 23.3 (20.1–26.5) | 26.8 (23.5–30.1) | 25.9 (22.3–29.5) | 32.9 (24.2–41.7) | 19.7 (13.4–26.0) | 30.7 (24.5–36.9) | —^d^ | —^d^
Smokeless tobacco
Past-year quit attempt | 43.6 (39.1–48.1) | —^d^ | 33.9 (30.0–37.7) | —^d^ | 42.5 (34.9–50.1) | —^d^ | —^d^ | —^d^
Sustained quit ≥6 months | 19.2 (15.7–22.8) | —^d^ | 12.4 (9.8–15.0) | —^d^ | 14.0 (8.7–19.4) | —^d^ | —^d^ | —^d^

Source: TUS-CPS, National Cancer Institute, public use data, 2018–2019.

Notes: CI = confidence interval.

a Assessment of a past-year quit attempt for cigarette smoking differed from the assessment of a past-year quit attempt for other tobacco products (cigars, e-cigarette, smokeless tobacco). For cigarette smoking, the assessment included (a) people who currently smoked cigarettes and who tried to quit completely during the past 12 months, who attempted to quit for at least 1 day during the past 12 months, and who made serious efforts to quit smoking even if it lasted less than 1 day during the past 12 months and (b) people who quit smoking during the past 12 months. For other tobacco products, the assessment included people who currently used the respective tobacco product who tried to quit for 1 day or longer during the past 12 months and people who quit using the respective tobacco product during the past 12 months.

b Assessment of a sustained quit from cigarette smoking for 6 or more months differed from the assessment of a sustained quit from other tobacco products (cigars, e-cigarettes, smokeless tobacco) for 6 or more months. For cigarette smoking, the assessment included people who quit smoking for 6–12 months before the interview, among people who currently smoked cigarettes for at least 2 years and among people who quit smoking during the past 12 months. For other tobacco products, the assessment included people who quit using the respective tobacco product 6–12 months before the interview, among people who currently used the respective tobacco product and people who quit using the respective tobacco product during the past 12 months. The assessment did not include a variable to assess the 2-year use duration for cigars, e-cigarettes, and smokeless tobacco.

c The white collar category included the following 2010 U.S. Census occupation classification codes: 0010-0950 (management, business, and financial occupations), 1000-3540 (professional and related occupations), 4700-4965 (sales and related occupations), and 5000-5940 (office and administrative support occupations). The maanual labor (blue collar) category included the following 2010 U.S. Census occupation classification codes: 6200-6940 (construction and extraction occupations), 7000-7630 (installation, maintenance, and repair occupations), 7700-8965 (production occupations), and 9000-9750 (transportation and material moving occupations). The service category included the following occupation classification code: 3600-4650 (service occupations). The other category included the following occupation classification codes: 6000-6130 (farming, fishing and forestry occupations) and 9840 (armed forces). Not Categorized included responses for which occupations could not be categorized.

d Unstable estimate is not presented because of a relative standard error >30% or unweighted denominator <50.

When examining tobacco use by type of disability and degree of difficulty performing certain tasks in the 2019 NHIS, Schulz and colleagues (2022b) found that the prevalence of current cigarette use was higher among adults who reported “a lot of difficulty/cannot do at all” than it was among adults who reported “no difficulty” to questions about vision (21.5%; 95% CI, 17.3–26.4 vs. 13.1%; 95% CI, 12.5–13.6), hearing (19.6%; 95% CI, 16.0–23.8 vs. 13.6%; 95% CI, 13.0–14.2), mobility (20.0%; 95% CI, 17.8–22.4 vs. 12.9%; 95% CI, 12.3–13.5), and cognitive (25.4%; 95% CI, 21.6–29.7 vs. 12.9%; 95% CI, 12.3–13.4) disabilities. The odds of current cigarette, pipe, and smokeless tobacco use were significantly higher among adults who reported “a lot of difficulty/cannot do at all” to any disability question (adjusted odds ratio [aOR] range = 1.32–1.85) and significantly higher for current cigarette, e-cigarette, pipe, and smokeless tobacco use for adults who reported “some difficulty” to any disability (aOR range = 1.24–1.45) compared with adults who reported “no difficulty.” Pipe use was correlated with a response of “a lot of difficulty/cannot do at all” in mobility (aOR = 1.68) while smokeless tobacco use was correlated with “a lot of difficulty/cannot do at all” in hearing (aOR = 1.95) (Schulz et al. 2022b).

Disability status was only added to the NSDUH in 2015 and a study of NSDUH data from 2015 to 2019 showed that in each year, there were overall declines in the prevalence of current cigarette smoking, but the prevalence of current smoking remained higher among people with disabilities compared to their counterparts without disabilities during this time period (Schulz et al. 2022a). According to these data, people with cognitive, independent living, and self-care disabilities experienced the highest prevalence of past-month daily cigarette use for all years. With respect to smoking cessation, the odds of former smoking were similar between people with any disability and those with no disability (aOR = 1.00; 95% CI, 0.95–1.06). Further examination of cessation by type of disability showed that people with a cognitive (aOR = 0.79; 95% CI, 0.71–0.87), independent living (aOR = 0.84; 95% CI, 0.77–0.93), self-care (aOR = 0.81; 95% CI, 0.72–0.92), or visual (aOR = 0.78; 95% CI, 0.70–0.87) disability had significantly lower odds of being a former smoker than those without such disabilities; people with a hearing disability had significantly higher odds of being a former smoker (aOR = 1.39; 95% CI, 1.27–1.51) than those who did not have a hearing disability (Schulz et al. 2022a).

Although people with disabilities disproportionately use tobacco products compared with people with no disabilities, research and tailored interventions to reduce tobacco use in this population remain scarce.

## Tobacco Use by Mental Health and Substance Use Status

Since the 1990s, a higher prevalence of smoking and use of other forms of tobacco has persisted among adults living with mental health conditions. Although smoking has declined among the rest of the population, few changes have been observed among people with mental health conditions, creating a wide disparity in tobacco use by mental health status in the United States and in England (Cook et al. 2014; Steinberg et al. 2015; Szatkowski and McNeill 2015; Weinberger et al. 2020). Given the persistent social stigma associated with behavioral health conditions (i.e., mental health conditions and substance use disorders) and increasing social stigmas toward people who use tobacco products, people with these conditions who also use tobacco products have become an increasingly socially isolated population (Brown-Johnson et al. 2015). The following sections use data from the NSDUH and cited literature to review tobacco use by mental health or substance use statuses among adults and youth.

The NSDUH captures data and self-reported information about mental health conditions^5^ or substance use disorders, including lifetime and past-year major depressive episode, serious psychological distress, and past-year alcohol or drug use disorder.

### Patterns of Ever and Current Use of Cigarettes

#### Youth

Data from the 2019 NSDUH show that among youth overall, the prevalence of past-month cigarette smoking was 2.4% (95% CI, 2.0–2.7); and among youth 12–17 years of age, the prevalence of ever and past-month cigarette use was higher among those with past-year alcohol use disorder, drug use disorder, or major depressive episode (Table 2.22, Part A). The prevalence of past-month smoking was 3.9% (95% CI, 3.0–4.8) among youth with a past-year major depressive episode, 4.0% (95% CI, 3.1–4.8) among youth with a lifetime major depressive episode, 17.4% (95% CI, 12.9–21.8) among youth with a past-year illicit drug use disorder, 19.7% (95% CI, 14.1–25.2) among youth with a past-year alcohol use disorder, and 30.0% (95% CI, 21.9–38.0) among youth with past-year alcohol and illicit drug use disorders (Table 2.22, Part A).

#### Adults

Analyses of NESARC data over time indicate a higher prevalence of ever or past-year cigarette smoking among people living with a mental health condition compared with people living without a mental health condition (Smith et al. 2014a, 2020b; Parker and Villanti 2021). Ever cigarette use was significantly higher among people with any past-year mental health condition (53.6%) compared with people with no past-year mental health condition (36.4%); this pattern was consistent across all specific conditions that were assessed (Smith et al. 2020b). According to Smith and colleagues (2020b), the prevalence of past-year cigarette smoking among those with any past-year mental health condition was also higher (33.3%) compared to those with no past-year mental health condition (17.2%).

Table 2.22 presents 2019 NSDUH data on the prevalence of tobacco product use by current and lifetime mental health conditions or substance use disorders. The prevalence of ever cigarette use was high among adults with past-year illicit drug and alcohol use disorders (91.2%; 95% CI, 84.7–97.7) and adults with a serious mental health condition during the past year (72.4%; 95% CI, 69.3–75.5) (Table 2.22, Part A). Ever cigarette use was higher among adults reporting serious psychological distress in the past month (69.9%; 95% CI, 67.0–72.7) than it was among adults without such distress (58.4%; 95% CI, 57.7–59.2). Among all adults, the prevalence of past-month cigarette use was 18.5% (95% CI, 18.1–19.0). The prevalence of past-month cigarette use was 56.7% (95% CI, 46.8–66.6) among adults with a past-year illicit drug and alcohol use disorder. Among adults with any serious mental health condition during the past year, 30.9% (95% CI, 28.0–33.8) reported past-month cigarette use (Table 2.22, Part A). Similarly, past-month cigarette use was higher among adults reporting serious psychological distress in the past month (35.2%; 95% CI, 32.5–37.9) than it was among adults without such distress (17.4%; 95% CI, 16.9–17.9) (Table 2.22, Part A).

### Patterns of Frequency and Quantity of Cigarette Use

Table 2.23 shows that, among adults who smoke, the prevalence of daily smoking is similar by mental health status. According to data from the NSDUH for 2019, the mean number of cigarettes smoked during the past month was similar among adults without any mental health condition (291 cigarettes) and adults with any mental health condition (288 cigarettes) (NSDUH, public use data, 2019). As shown in Figure 2.9, in 2019, regardless of gender and mental health status, the average number of cigarettes smoked by adults during the past month increased by age category. For all genders and across all age groups, no differences in the average number of cigarettes smoked during the past month were observed by past-year mental health status. Among men and women living with any mental health condition in the past year, 18- to 25-year-olds smoked 134 cigarettes on average during the past month; 26- to 49-year-olds smoked 295 cigarettes on average; and those 50 years of age and older smoked 352 cigarettes on average (NSDUH, public use data, 2019). Men living with any mental health condition in the past year smoked 300 cigarettes on average in the past month compared with 279 cigarettes for women living with any mental health condition in the past year.

Focusing on 2005–2014 data from the NSDUH, Weinberger and colleagues (2018) conducted time-trend analyses of smoking behaviors among people with and without past-year mental health conditions (defined as a major depressive episode or serious psychological distress) or substance use disorders (defined as alcohol or other substance use disorder, heavy alcohol use, or daily cannabis use). Overall, the prevalence of daily cigarette smoking declined significantly between 2005 and 2014 among people with mental health conditions or substance use disorders (from 29.4% in 2005 to 24.2% in 2014) and among people without mental health conditions or substance use disorders (from 13.5% in 2005 to 10.2% in 2014). In contrast, the prevalence of nondaily cigarette use increased between 2005 and 2014 among people with mental health conditions or substance use disorders (from 29.5% in 2005 to 33.7% in 2014) but decreased among those without mental health conditions or substance use disorders (from 29.1% in 2005 to 27.4% in 2014). As a result, the disparity in nondaily cigarette use increased between people with and without mental health conditions or substance use disorders, and in 2014, the prevalence of current, daily, and nondaily cigarette smoking all remained significantly higher among people with mental health conditions or substance use disorders than it was among people without such disorders (Weinberger et al. 2018).

Table 2.22 Age-adjusted prevalence of patterns of tobacco product use, by mental health conditions or substance use disorders; National Survey on Drug Use and Health (NSDUH) 2019, United States

A Overall prevalence of mental health conditions or substance use disorders, current use of two or more tobacco products, and ever and current use of cigarettes

Age group and mental health conditions and substance use disordersa | Overall prevalence of mental health conditions | | Current use of ≥2 tobacco products^a^ | | Ever use of cigarettes^b^ | | Current use of cigarettes^c^
Age group and mental health conditions and substance use disordersa | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI)
Adults and youth (≥12 years of age) (n = 56,136)
Prevalence of ever and current use of tobacco products—overall | — | — | 2,169 | 3.3 (3.1–3.5) | 25,671 | 54.4 (53.8–55.1) | 9,142 | 17.0 (16.5–17.4)
Past-year alcohol use disorder^d^ | 3,363 | 5.4 (5.2–5.7) | 474 | 10.4 (8.8–11.9) | 2,725 | 82.7 (80.5–84.8) | 1,384 | 37.0 (34.2–39.7)
Past-year illicit drug use disorder^e^ | 2,385 | 3.2 (3.0–3.4) | 409 | 14.6 (11.8–17.4) | 1,897 | 86.8 (84.5–89.1) | 1,102 | 45.1 (40.8–49.3)
Past-year illicit drug or alcohol disorder^f^ | 5,061 | 7.7 (7.4–8.0) | 719 | 10.3 (9.0–11.6) | 4,027 | 82.7 (80.9–84.4) | 2,112 | 37.8 (35.6–40.1)
Past-year illicit drug and alcohol use disorder^g^ | 687 | 0.9 (0.8–1.0) | 164 | 27.6 (18.0–37.1) | 595 | 89.6 (83.7–95.6) | 374 | 54.8 (45.7–63.8)
Adults (≥18 years of age) (n = 42,739)
Prevalence of ever and current use of tobacco products—overall | — | — | 2,007 | 3.5 (3.3–3.7) | 24,320 | 59.3 (58.6–60.0) | 8,781 | 18.5 (18.1–19.0)
Serious psychological distress during the past month^h^
Yes | 4,148 | 6.9 (6.6–7.2) | 405 | 8.1 (6.6–9.6) | 2,678 | 69.9 (67.0–72.7) | 1,398 | 35.2 (32.5–37.9)
No | 38,591 | 93.1 (92.8–93.4) | 1,602 | 3.2 (3.0–3.4) | 21,642 | 58.4 (57.7–59.2) | 7,383 | 17.4 (16.9–17.9)
Serious psychological distress during the past year^i^
Yes | 7,664 | 13.0 (12.5–13.4) | 610 | 6.9 (5.8–8.1) | 4,834 | 68.8 (66.7–70.9) | 2,241 | 30.6 (28.6–32.7)
No | 35,075 | 87.0 (86.6–87.5) | 1,397 | 3.1 (2.9–3.3) | 19,486 | 57.7 (57.0–58.5) | 6,540 | 17.0 (16.5–17.4)
Past-year alcohol use disorder | 3,107 | 5.8 (5.5–6.1) | 437 | 9.6 (8.0–11.1) | 2,564 | 85.2 (83.0–87.4) | 1,301 | 37.7 (34.9–40.5)
Past-year illicit drug use disorder | 1,868 | 3.1 (2.9–3.3) | 339 | 14.6 (11.6–17.7) | 1,624 | 90.7 (88.3–93.2) | 979 | 47.6 (42.9–52.2)
Past-year illicit drug or alcohol disorder | 4,405 | 8.0 (7.7–8.4) | 636 | 9.9 (8.5–11.2) | 3,683 | 86.3 (84.4–88.1) | 1,956 | 39.5 (37.1–42.0)
Past-year illicit drug and alcohol use disorder | 570 | 0.9 (0.8–1.0) | 140 | 27.8 (17.3–38.3) | 505 | 91.2 (84.7–97.7) | 324 | 56.7 (46.8–66.6)
Lifetime major depressive episode^j^ | 7,552 | 14.6 (14.1–15.1) | 477 | 4.3 (3.7–4.9) | 4,943 | 70.2 (68.6–71.9) | 1,904 | 23.1 (21.7–24.4)
Past-year major depressive episode^k^ | 4,467 | 8.2 (7.8–8.5) | 335 | 5.0 (4.0–6.0) | 2,904 | 69.5 (66.9–72.1) | 1,258 | 26.7 (24.6–28.8)
Suicidal thoughts during the past year^l^ | 3,071 | 5.1 (4.8–5.3) | 297 | 7.0 (5.7–8.3) | 1,981 | 71.2 (67.8–74.6) | 927 | 26.0 (23.4–28.7)
Suicidal plans during the past year^m^ | 962 | 1.4 (1.3–1.6) | 128 | 9.9 (6.5–13.2) | 634 | 68.0 (60.6–75.5) | 332 | 28.4 (23.0–33.8)
A suicide attempt during the past year^n^ | 431 | 0.6 (0.5–0.7) | 69 | 7.4 (4.7–10.1) | 283 | 62.5 (49.1–75.8) | 162 | 24.8 (20.9–28.6)
Any mental health condition during the past year^o^ | 10,796 | 21.2 (20.6–21.7) | 750 | 5.4 (4.8–6.0) | 7,018 | 69.3 (67.9–70.7) | 3,047 | 26.8 (25.6–28.0)
Serious mental health condition during the past year^o^ | 3,005 | 5.5 (5.2–5.8) | 245 | 5.6 (4.4–6.8) | 2,100 | 72.4 (69.3–75.5) | 996 | 30.9 (28.0–33.8)
Mild or moderate mental health condition during the past year^o^ | 7,791 | 15.7 (15.2–16.2) | 505 | 5.3 (4.5–6.0) | 4,918 | 68.1 (66.5–69.7) | 2,051 | 25.4 (24.0–26.8)
Youth (12–17 years of age) (n = 13,397)
Prevalence of ever and current use of tobacco products—overall | — | — | 162 | 1.2 (1.0–1.5) | 1,351 | 9.4 (8.8–10.0) | 361 | 2.4 (2.0–2.7)
Past-year alcohol use disorder | 256 | 1.7 (1.5–2.0) | 37 | 12.1 (7.1–17.1) | 161 | 52.4 (45.3–59.5) | 83 | 19.7 (14.1–25.2)
Past-year illicit drug use disorder | 517 | 3.8 (3.4–4.3) | 70 | 11.6 (8.1–15.1) | 273 | 44.7 (37.2–52.1) | 123 | 17.4 (12.9–21.8)
Past-year illicit drug or alcohol disorder | 656 | 4.7 (4.2–5.2) | 83 | 10.9 (7.8–13.9) | 344 | 44.5 (37.3–51.7) | 156 | 17.1 (13.1–21.0)
Past-year illicit drug and alcohol use disorder | 117 | 0.8 (0.6–1.0) | 24 | 21.5 (12.1–30.9) | 90 | 67.3 (60.3–74.2) | 50 | 30.0 (21.9–38.0)
Lifetime major depressive episode | 2,869 | 21.9 (21.0–22.7) | 56 | 1.8 (1.1–2.4) | 508 | 14.4 (12.8–15.9) | 151 | 4.0 (3.1–4.8)
Past-year major depressive episode | 2,098 | 15.8 (15.0–16.6) | 40 | 1.4 (0.8–2.1) | 392 | 15.2 (13.4–17.1) | 112 | 3.9 (3.0–4.8)

B Ever and current use of cigars and pipes

Age group and mental health conditions and substance use disordersa | Ever use of cigars^p^ | | Current use of cigars^q^ | | Ever use of pipes^r^ | | Current use of pipes^s^
Age group and mental health conditions and substance use disordersa | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI)
Adults and youth (≥12 years of age) (n = 56,136)
Prevalence of ever and current use of tobacco products—overall | 15,443 | 31.2 (30.7–31.8) | 2,638 | 4.4 (4.1–4.6) | 4,703 | 10.9 (10.5–11.4) | 486 | 0.7 (0.6–0.8)
Past-year alcohol use disorder^d^ | 1,955 | 60.1 (56.8–63.4) | 440 | 12.0 (9.9–14.2) | 689 | 24.1 (21.0–27.1) | 106 | 2.3 (1.6–3.0)
Past-year illicit drug use disorder^e^ | 1,356 | 55.7 (50.4–60.9) | 438 | 15.2 (11.4–19.0) | 516 | 29.8 (25.1–34.4) | 108 | 3.1 (2.1–4.0)
Past-year illicit drug or alcohol disorder^f^ | 2,877 | 58.8 (55.7–61.8) | 734 | 12.4 (10.5–14.3) | 1,033 | 25.4 (22.9–28.0) | 174 | 2.4 (1.8–3.1)
Past-year illicit drug and alcohol use disorder^g^ | 434 | 63.7 (57.4–70.0) | 144 | 24.2 (14.6–33.7) | 172 | 29.1 (20.2–38.0) | 40 | 3.5 (1.6–5.3)
Adults (≥18 years of age) (n = 42,739)
Prevalence of ever and current use of tobacco products—overall | 14,715 | 34.1 (33.4–34.7) | 2,441 | 4.7 (4.4–4.9) | 4,500 | 12.0 (11.5–12.4) | 434 | 0.8 (0.7–0.9)
Serious psychological distress during the past month^h^
Yes | 1,644 | 37.6 (34.6–40.7) | 414 | 7.2 (5.9–8.5) | 546 | 15.7 (13.2–18.3) | 105 | 2.8 (1.8–3.9)
No | 13,071 | 33.7 (33.0–34.4) | 2,027 | 4.5 (4.2–4.7) | 3,954 | 11.7 (11.2–12.1) | 329 | 0.6 (0.5–0.7)
Serious psychological distress during the past year^i^
Yes | 3,046 | 38.4 (36.0–40.8) | 663 | 7.0 (5.9–8.2) | 959 | 15.3 (13.4–17.2) | 151 | 2.0 (1.4–2.7)
No | 11,669 | 33.3 (32.6–34.0) | 1,778 | 4.3 (4.1–4.6) | 3,541 | 11.4 (11.0–11.9) | 283 | 0.6 (0.5–0.7)
Past-year alcohol use disorder | 1,857 | 62.3 (58.7–65.8) | 407 | 11.7 (9.4–13.9) | 655 | 25.3 (21.9–28.7) | 94 | 2.0 (1.3–2.7)
Past-year illicit drug use disorder | 1,172 | 57.6 (51.9–63.3) | 359 | 15.0 (10.9–19.2) | 453 | 31.6 (26.5–36.8) | 89 | 3.0 (1.9–4.0)
Past-year illicit drug or alcohol disorder | 2,646 | 61.2 (57.8–64.5) | 642 | 12.2 (10.1–14.2) | 956 | 26.9 (24.0–29.7) | 152 | 2.3 (1.7–3.0)
Past-year illicit drug and alcohol use disorder | 383 | 65.4 (58.6–72.3) | 124 | 24.0 (13.5–34.5) | 152 | 30.6 (20.7–40.4) | 31 | 3.1 (1.1–5.1)
Lifetime major depressive episode^j^ | 3,152 | 40.3 (38.2–42.3) | 549 | 5.8 (4.9–6.7) | 1,018 | 15.9 (14.1–17.6) | 111 | 0.9 (0.7–1.2)
Past-year major depressive episode^k^ | 1,896 | 40.9 (38.3–43.5) | 383 | 6.7 (5.2–8.1) | 616 | 17.7 (15.4–20.0) | 79 | 1.2 (0.8–1.6)
Suicidal thoughts during the past year^l^ | 1,310 | 44.1 (40.5–47.7) | 323 | 7.6 (6.1–9.2) | 452 | 20.2 (17.1–23.4) | 73 | 1.4 (0.8–2.0)
Suicidal plans during the past year^m^ | 396 | 40.2 (33.0–47.4) | 114 | 8.1 (5.4–10.8) | 158 | 18.3 (12.2–24.4) | 33 | 2.0 (0.9–3.1)
A suicide attempt during the past year^n^ | 170 | 31.4 (21.0–41.8) | 62 | 6.8 (4.0–9.5) | —^t^ | —^t^ | 19 | 1.7 (1.1–2.3)
Any mental health condition during the past year^o^ | 4,393 | 39.1 (37.6–40.5) | 848 | 6.2 (5.5–6.9) | 1,402 | 15.7 (14.5–17.0) | 182 | 1.4 (1.0–1.7)
Serious mental health condition during the past year^o^ | 1,317 | 41.1 (37.6–44.6) | 274 | 6.5 (5.1–8.0) | 439 | 18.2 (15.1–21.4) | 62 | 1.5 (0.9–2.1)
Mild or moderate mental health condition during the past year^o^ | 3,076 | 38.5 (37.0–40.1) | 574 | 6.0 (5.2–6.8) | 963 | 15.2 (13.7–16.6) | 120 | 1.3 (0.9–1.7)
Youth (12–17 years of age) (n = 13,397)
Prevalence of ever and current use of tobacco products—overall | 728 | 5.3 (4.8–5.8) | 197 | 1.5 (1.2–1.7) | 203 | 1.5 (1.2–1.7) | 52 | 0.4 (0.2–0.5)
Past-year alcohol use disorder | 98 | 34.2 (24.6–43.8) | 33 | 13.6 (6.1–21.2) | —^t^ | —^t^ | —^t^ | —^t^
Past-year illicit drug use disorder | 184 | 30.4 (23.9–37.0) | 79 | 12.7 (9.3–16.1) | 63 | 13.3 (7.2–19.3) | —^t^ | —^t^
Past-year illicit drug or alcohol disorder | 231 | 30.4 (23.9–36.9) | 92 | 11.5 (8.5–14.4) | 77 | 13.1 (7.1–19.0) | 22 | 2.6 (1.1–4.1)
Past-year illicit drug and alcohol use disorder | 51 | 34.0 (24.8–43.3) | 20 | 21.4 (11.7–31.1) | —^t^ | —^t^ | —^t^ | —^t^
Lifetime major depressive episode | 241 | 7.3 (6.1–8.4) | 64 | 2.1 (1.5–2.8) | 84 | 2.4 (1.7–3.2) | 21 | 0.5 (0.2–0.7)
Past-year major depressive episode | 177 | 7.1 (5.7–8.5) | 49 | 2.0 (1.3–2.8) | 68 | 2.8 (1.8–3.7) | —^t^ | —^t^

C Ever and current use of combustible and smokeless tobacco products

Age group and mental health conditions and substance use disordersa | Ever use of combustible tobacco products^u^ | | Current use of combustible tobacco products^v^ | | Ever use of smokeless tobacco products^w^ | | Current use of smokeless tobacco products^x^
Age group and mental health conditions and substance use disordersa | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI)
Adults and youth (≥12 years of age) (n = 56,136)
Prevalence of ever and current use of tobacco products—overall | 28,461 | 59.4 (58.8–60.0) | 10,681 | 19.6 (19.1–20.0) | 8,526 | 15.7 (15.3–16.2) | 1,996 | 3.2 (3.0–3.4)
Past-year alcohol use disorder^d^ | 2,918 | 87.9 (86.0–89.7) | 1,584 | 43.2 (40.3–46.1) | 1,219 | 32.0 (29.1–35.0) | 333 | 7.1 (5.8–8.3)
Past-year illicit drug use disorder^e^ | 2,055 | 91.0 (89.2–92.9) | 1,298 | 50.7 (46.3–55.1) | 781 | 32.2 (27.6–36.9) | 184 | 5.9 (4.6–7.2)
Past-year illicit drug or alcohol disorder^f^ | 4,340 | 88.0 (86.5–89.5) | 2,459 | 44.4 (41.9–46.8) | 1,717 | 31.2 (28.7–33.7) | 435 | 6.3 (5.3–7.3)
Past-year illicit drug and alcohol use disorder^g^ | 633 | 94.0 (90.8–97.2) | 423 | 58.5 (49.5–67.5) | 283 | 41.0 (30.3–51.8) | 82 | 9.1 (6.0–12.2)
Adults (≥18 years of age) (n = 42,739)
Prevalence of ever and current use of tobacco products—overall | 26,806 | 64.5 (63.9–65.2) | 10,195 | 21.3 (20.8–21.8) | 7,936 | 17.0 (16.5–17.5) | 1,852 | 3.4 (3.2–3.6)
Serious psychological distress during the past month^h^
Yes | 2,896 | 74.0 (71.4–76.6) | 1,569 | 37.6 (34.8–40.4) | 863 | 17.6 (15.7–19.4) | 220 | 4.0 (3.0–5.1)
No | 23,910 | 63.8 (63.1–64.4) | 8,626 | 20.2 (19.6–20.7) | 7,073 | 16.9 (16.4–17.4) | 1,632 | 3.4 (3.2–3.6)
Serious psychological distress during the past year^i^
Yes | 5,268 | 73.2 (71.2–75.2) | 2,541 | 33.3 (31.1–35.4) | 1,507 | 16.9 (15.4–18.4) | 341 | 3.4 (2.6–4.1)
No | 21,538 | 63.1 (62.4–63.8) | 7,654 | 19.7 (19.2–20.2) | 6,429 | 17.0 (16.4–17.5) | 1,511 | 3.5 (3.2–3.7)
Past-year alcohol use disorder | 2,734 | 90.0 (88.2–91.9) | 1,488 | 44.0 (41.0–47.1) | 1,142 | 32.3 (29.2–35.5) | 311 | 6.8 (5.5–8.1)
Past-year illicit drug use disorder | 1,731 | 94.3 (92.3–96.2) | 1,139 | 52.9 (48.1–57.8) | 672 | 33.3 (28.1–38.5) | 154 | 5.8 (4.4–7.3)
Past-year illicit drug or alcohol disorder | 3,929 | 91.0 (89.4–92.6) | 2,259 | 46.0 (43.4–48.7) | 1,577 | 32.2 (29.5–34.9) | 394 | 6.2 (5.1–7.3)
Past-year illicit drug and alcohol use disorder | 536 | 95.3 (91.9–98.8) | 368 | 60.1 (50.2–70.0) | 237 | 40.9 (29.1–52.7) | 71 | 9.0 (5.7–12.3)
Lifetime major depressive episode^j^ | 5,358 | 74.8 (73.2–76.4) | 2,180 | 26.3 (24.8–27.8) | 1,514 | 17.6 (16.3–18.9) | 261 | 2.6 (2.2–3.0)
Past-year major depressive episode^k^ | 3,156 | 74.7 (72.2–77.1) | 1,446 | 30.4 (28.1–32.6) | 887 | 17.7 (15.7–19.8) | 163 | 2.6 (1.9–3.2)
Suicidal thoughts during the past year^l^ | 2,159 | 76.0 (73.0–79.1) | 1,068 | 29.4 (26.5–32.3) | 677 | 20.3 (17.2–23.4) | 149 | 4.0 (2.8–5.3)
Suicidal plans during the past year^m^ | 687 | 73.4 (66.4–80.3) | 370 | 30.6 (25.1–36.1) | 230 | 20.0 (15.0–25.0) | 62 | 5.6 (2.8–8.5)
A suicide attempt during the past year^n^ | 308 | 67.8 (54.5–81.1) | 184 | 27.2 (23.6–30.7) | 105 | 14.1 (8.4–19.7) | 33 | 3.6 (1.8–5.5)
Any mental health condition during the past year^o^ | 7,587 | 73.8 (72.5–75.1) | 3,449 | 29.7 (28.5–31.0) | 2,170 | 17.5 (16.4–18.6) | 436 | 3.0 (2.5–3.4)
Serious mental health condition during the past year^o^ | 2,246 | 76.9 (73.8–80.0) | 1,118 | 34.0 (30.9–37.1) | 621 | 16.8 (14.6–19.0) | 108 | 2.6 (1.8–3.3)
Mild or moderate mental health condition during the past year^p^ | 5,341 | 72.6 (71.2–74.1) | 2,331 | 28.2 (26.8–29.6) | 1,549 | 17.7 (16.5–19.0) | 328 | 3.1 (2.6–3.6)
Youth (12–17 years of age) (n = 13,397)
Prevalence of ever and current use of tobacco products—overall | 1,655 | 11.7 (11.0–12.3) | 486 | 3.3 (2.9–3.7) | 590 | 4.3 (3.9–4.7) | 144 | 1.0 (0.8–1.2)
Past-year alcohol use disorder | 184 | 58.0 (51.1–64.8) | 96 | 25.3 (17.2–33.3) | 77 | 36.4 (30.4–42.4) | 22 | 21.2 (18.3–24.1)
Past-year illicit drug use disorder | 324 | 54.2 (46.5–62.0) | 159 | 23.7 (18.4–29.0) | 109 | 22.3 (15.3–29.2) | —^t^ | —^t^
Past-year illicit drug or alcohol disorder | 411 | 53.8 (46.3–61.2) | 200 | 23.1 (18.4–27.8) | 140 | 21.2 (14.6–27.9) | 41 | 10.2 (4.2–16.1)
Past-year illicit drug and alcohol use disorder | 97 | 71.5 (65.3–77.8) | 55 | 33.2 (25.0–41.4) | 46 | 65.5 (58.0–73.1) | 11 | 21.0 (17.2–24.9)
Lifetime major depressive episode | 589 | 16.9 (15.3–18.6) | 187 | 5.0 (4.1–6.0) | 141 | 4.2 (3.4–5.1) | 39 | 1.0 (0.6–1.5)
Past year major depressive episode | 453 | 17.9 (15.9–19.9) | 144 | 5.1 (4.1–6.2) | 105 | 4.1 (3.1–5.1) | 27 | 0.9 (0.4–1.4)

Source: National Survey on Drug Use and Health, public use data, 2019.

Notes: Proportions and 95% CIs are age adjusted using the direct method based on the 2010 U.S. standard population. For the overall analyses, the denominator is the entire sample (n = 56,136) and the following age groups: 12–17, 18–25, 26–34, 35–49, and 50–64 years of age and 65 years of age and older. For the analyses of adults, the denominator is adults 18 years of age and older (n = 42,739) and the following age groups: 18–25, 26–34, 35–49, and 50–64 years of age and 65 years of age and older. For the analyses of youth, the denominator is youth 12–17 years of age (n = 13,397) and the age groups by single year: 12, 13, 14, 15, 16, and 17. CI = confidence interval; DSM IV = Diagnostic and Statistical Manual of Mental Disorders, 4th edition.

a Current use of two or more tobacco products was defined as having used any combination of two or more of the following products during the past 30 days: cigarettes, cigars, tobacco in a pipe, or smokeless tobacco (snuff, dip, chewing tobacco, or snus).

b Ever use of cigarettes was defined as having ever smoked part or all of a cigarette, even one time, during the lifetime.

c Current use of cigarettes was defined as having smoked part or all of a cigarette during the past 30 days.

d Past-year alcohol use disorder was defined as having met alcohol dependence or abuse criteria during the past 12 months.

e Past-year illicit drug use disorder was defined as having met dependence or abuse criteria during the past 12 months for any of the following illicit drugs: marijuana (cannabis), hallucinogens, inhalants, methamphetamine, tranquilizers, cocaine, heroin, pain relievers, stimulants, or sedatives.

f Past-year illicit drug or alcohol disorder was defined as having met criteria for past-year dependence or abuse of either alcohol or any of the illicit drugs during the past 12 months.

g Past-year illicit drug and alcohol use disorder was defined as having met criteria for past-year dependence or abuse of both alcohol and any of the illicit drugs during the past 12 months.

h Serious psychological distress during the past month was defined using the Kessler-6 measure. Respondents were rated on a Likert scale for how frequently they experienced the following symptoms of psychological distress during the past 30 days: (1) nervousness, (2) hopelessness, (3) feeling restless or fidgety, (4) feeling so depressed that nothing could cheer them up, (5) feeling that everything was an effort, and (6) feeling worthless. Responses were coded as follows: ‘‘all of the time’’ was coded as 4; ‘‘most of the time’’ as 3; ‘‘some of the time’’ as 2; ‘‘a little of the time’’ as 1; and ‘‘none of the time’’ as 0. Response codes 0–4 were summed to yield a score range of 0–24. Serious psychological distress was defined as a value of 13 or more.

i Serious psychological distress during the past year was defined based on the higher score between the past-month Kessler-6 items and the worst month of Kessler-6 items during the 12 months. After responding to Kessler-6 items for the past month, respondents were asked if there was a month during the past 12 months when they felt more depressed, anxious, or emotionally stressed than they had felt during the past 30 days. This level of psychological distress is referenced as the “worst month in past year.”

j Lifetime major depressive episode was defined as having experienced at least five of the nine criteria used to define having had a major depressive episode during the lifetime, where at least one of the criteria is a depressed mood or loss of interest or pleasure in daily activities. To screen for major depressive episode, youth and adults were asked separate sets of questions.

k Past-year major depressive episode was defined as having met criteria for major depressive episode during the past 12 months. Youth and adults were asked separate sets of questions.

l Suicidal thoughts during the past year was defined as a positive response to the following question: “At any time during the past 12 months, that is from [DATE] up to and including today, did you seriously think about trying to kill yourself?”

m Suicidal plans during the past year was defined as a positive response to the following question: “During the past 12 months, did you make any plans to kill yourself?”

n A suicide attempt during the past year was defined as a positive response to the following question: “During the past 12 months, did you try to kill yourself?”

o Any, serious, and mild or moderate mental health conditions during the past year was defined based on the predicted probability model developed using a subsample of NSDUH respondents who underwent a diagnostic interview via a clinical follow-up study.

p Ever use of cigars was defined as having ever smoked part or all of any type of cigar, even one time, during the lifetime.

q Current use of cigars was defined as having smoked part or all of any type of cigar during the past 30 days.

r Ever use of pipes was defined as having ever smoked tobacco in a pipe, waterpipe, or hookah, even one time, during the lifetime.

s Current use of pipes was defined as having ever smoked tobacco in a pipe, water pipe, or hookah during the past 30 days.

t Standard error >30% of the point estimate (percentage) or the unweighted denominator is <50.

u Ever use of combustible tobacco products was defined as having ever smoked part or all of a cigarette; part or all of any type of cigar; or tobacco in a pipe, waterpipe, or hookah, even one time, during the lifetime.

v Current use of combustible tobacco products was defined as having ever smoked part or all of a cigarette, part or all of any type of cigar; or tobacco in a pipe, waterpipe, or hookah during the past 30 days.

w Ever use of smokeless tobacco was defined as having ever used smokeless tobacco (such as, snuff, dip, chewing tobacco, or snus), even one time, during the lifetime.

x Current use of smokeless tobacco was defined as having used smokeless tobacco (such as, snuff, dip, chewing tobacco, or snus) during the past 30 days.

Table 2.23 Age-adjusted percentage of smoking frequency and quit smoking status among adults who smoked cigarettes, by mental health status; National Survey on Drug Use and Health (NSDUH) 2019, United States

Smoking frequency and quit smoking status | No past-year any mental health condition^a^ | | With past year any mental health condition^a^ | | Any excluding serious mental health condition^b^ | | Serious mental health condition^c^
Smoking frequency and quit smoking status | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI) | Unweighted frequency | Weighted % (age adjusted) (95% CI)
Smoking frequency^d^
Every day (30 days) | 3,107 | 58.4 (56.4–60.3) | 1,689 | 61.3 (58.6–64.1) | 1,129 | 60.8 (57.6–64.0) | 560 | 62.0 (55.1–68.8)
Some days (1–29 days) | 2,627 | 41.6 (39.7–43.6) | 1,358 | 38.7 (35.9–41.4) | 922 | 39.2 (36.0–42.4) | 436 | 38.0 (31.2–44.9)
Total | 5,734 | — | 3,047 | — | 2,051 | — | 996 | —
Quit smoking status^e^
Never quit or quit for ≤30 days^f^ | 5,788 | 29.8 (29.0–30.6) | 3,066 | 39.0 (37.4–40.7) | 2,068 | 37.7 (35.9–39.5) | 998 | 42.7 (38.9–46.4)
Quit for >30 days but <1 year^g^ | 1,461 | 6.8 (6.4–7.2) | 734 | 7.6 (6.7–8.5) | 504 | 8.0 (7.0–9.1) | 230 | 5.9 (4.8–7.1)
Quit for 1 year or more^h^ | 10,029 | 63.4 (62.5–64.3) | 3,198 | 53.4 (51.7–55.1) | 2,336 | 54.3 (52.4–56.1) | 862 | 51.4 (47.6–55.2)
Total | 17,278 | — | 6,998 | — | 4,908 | — | 2,090 | —

Source: NSDUH, National Survey on Drug Use and Health, public use data, 2019.

Notes: Proportions and 95% confidence intervals are age adjusted using the direct method based on the 2010 U.S. standard population for the following age groups: 18–25, 26–34, 35–49, and 50–64 years of age and 65 years of age and older. CI = confidence intervals.

a Any mental health condition was defined as having a serious, moderate, or mild mental health condition.

b Any excluding serious mental condition was defined as having a mild or moderate mental health condition.

c Serious mental health condition was defined as having a diagnosable mental, behavioral, or emotional disorder resulting in serious functional impairment.

d Smoking frequency was defined as every day (if the respondent smoked cigarettes on 30 days during the 30 days before the interview) and as some days (if the respondent smoked cigarettes on 1–29 days during the 30 days before the interview.

e Cigarette smoking cessation estimates were calculated among those who responded “Yes” to “Have you ever smoked part or all of a cigarette?”

f Among ever cigarette smokers, respondent answered “Within the past 30 days” to the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

g Among ever cigarette smokers, respondent answered “More than 30 days ago but within the past 12 months.” to the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

h Among ever cigarette smokers, respondent answered “More than 12 months ago but within the past 3 years” or “More than 3 years ago” to the question, “Now think about the past 30 days, that is, from [DATEFILL] up to and including today. During the past 30 days, have you smoked part or all of a cigarette? How long has it been since you last smoked part or all of a cigarette?”

Figure 2.9 Average number of cigarettes smoked during the past month among adults, 18 years of age and older, who smoked during the past month, by status of past-year mental health condition,^a^ a Any mental health condition during the past year was defined based on the predicted probability model developed using a subsample of NSDUH respondents who underwent a diagnostic interview via a clinical follow-up study. Refer to NSDUH 2019 Codebook for more details. age group, and sex; National Survey on Drug Use and Health (NSDUH) 2019, United States

In 2019, the average number of cigarettes smoked by adults during the past month increased by age category, regardless to sex and mental health status. However, for men and women and across all age groups, no differences in the average number of cigarettes smoked during the past month were observed by past-year mental health status as noted by overlapping confidence intervals.

Source: NSDUH, Substance Abuse and Mental Health Services Administration, public use data, 2019.

### Patterns of Smoking Cessation

The 2012–2013 National Epidemiologic Survey on Alcohol and Related Conditions III (NESARC-III) is a U.S. survey that uses a population-based sample that includes both specific mental health diagnoses and cigarette use. Based on the Diagnostic and Statistical Manual of Mental Disorders, 5th edition, past-year mental health conditions were assessed using the Alcohol Use Disorder and Associated Disabilities Interview Schedule-5 (AUDADIS-5). In an analysis of 2012–2013 data from NESARC-III, Smith and colleagues (2020b) included the following diagnoses from the AUDADIS-5 in their analyses: major depressive episode, dysthymia, bipolar disorder, specific phobia, social phobia, panic disorder, agoraphobia, generalized anxiety disorder, posttraumatic stress disorder, any eating disorder, alcohol use disorder, and drug use disorder. The authors found that the prevalence of lifetime cessation—defined as having smoked at least 100 cigarettes in a lifetime (i.e., people who have ever smoked) and reporting having not smoked during the previous year—was lower among adults with a past-year mental health condition (39.4%) than it was among adults without such a past-year diagnosis (47.1%) after accounting for age, sex, race and ethnicity, and level of education and income. The prevalence of lifetime smoking cessation varied by mental health condition. Many of the lowest estimates of the prevalence of lifetime cessation were observed in adults who were also diagnosed with a substance use disorder, including a past-year diagnosis of drug use disorder (26.8%), dual substance use and nonsubstance mood or anxiety disorder (32.2%), and alcohol use disorder (32.9%). This finding may reflect, in part, a systemic failure to treat tobacco use in substance use treatment or mental healthcare settings (Prochaska 2010; Cohn et al. 2017; Marynak et al. 2018).

Smith and colleagues (2020b) also reported that the adjusted prevalence of lifetime smoking cessation among people who had ever smoked was significantly higher among people who had no mental health condition or substance use disorder (47.1%) than it was among people with various past-year mental health conditions that were not co-occurring with a substance use disorder. Specifically, the adjusted prevalence of lifetime cessation was lower among those with past-year bipolar disorder (29.2%), dysthymia (33.5%), panic disorder (33.5%), agoraphobia (36.3%), generalized anxiety disorder (36.5%), posttraumatic stress disorder (36.7%), major depressive episode (36.8%), and specific phobia and social phobia (39.7% each) (Smith et al. 2020b).

Analyses of 2019 data from the NSDUH show that the prevalence of recent quitting (having last smoked a cigarette more than 30 days ago but less than 1 year ago) was similar between adults with no past-year mental health condition (6.8%; 95% CI, 6.4–7.2) and adults with serious mental health conditions (5.9%; 95% CI, 4.8–7.1). However, the prevalence of quitting for at least 1 year differed significantly between adults with no past-year mental health condition (63.4%; 95% CI, 62.5–64.3) and adults with serious mental health conditions (51.4%; 95% CI, 47.6–55.2) (Table 2.23).

According to other data from the 2016 NSDUH, quit rates—defined as the proportion of people who used to smoke (those who have smoked 100 cigarettes in their lifetime but did not smoke in the past year) among people who ever smoked (those who have smoked at least 100 cigarettes in their lifetime)—were significantly lower among people with past-month serious psychological distress than they were among those without such distress (Streck et al. 2020). Additionally, quit rates among those without past-month serious psychological distress increased slightly between 2008 and 2016, but quit rates did not change among those with serious psychological distress (Streck et al. 2020).

### Patterns of Use of Other Tobacco Products

Table 2.22 shows data from the 2019 NSDUH related to tobacco product use by mental health conditions or substance use disorders in youth and adults.

#### E-Cigarettes

##### Youth

Baseline data from the PATH Study (2013–2014) documented a correlation between ever e-cigarette use and mental health conditions among youth 12–17 years of age (Conway et al. 2018) and higher odds of trying an e-cigarette among youth with high severity externalizing behavior (e.g., conduct, Attention Deficit Hyperactivity Disorder, oppositional/defiant problems) compared with youth with no, low, or moderate severity externalizing behavior (Green et al. 2018).

##### Adults

Cummins and colleagues (2014) used a national probability sample from 2012 and found that e-cigarette use in the United States was 2.8 times higher among people living with a mental health condition compared with people living without such a condition. Among people with a mental health condition, 3.1% (95% CI, 2.0–4.3) currently used e-cigarettes and 14.8% (95% CI, 12.4–17.2) ever used e-cigarettes. By comparison, among people without a mental health condition, 1.1% (95% CI, 0.8–1.4) currently used e-cigarettes and 6.6% (95% CI, 5.9–7.3) ever used e-cigarettes. Baseline data from the PATH Study also documented a correlation between current e-cigarette use and mental health conditions in U.S. adults (Conway et al. 2017). Using data from the 2014–2017 NHIS, Weinberger and colleagues (2020) found that the prevalence of e-cigarette use did not change significantly from 2014 to 2017 among adults with serious psychological distress (from 6.9% in 2014 to 7.4% in 2017), whereas a significant decrease in the prevalence of e-cigarette use was observed among individuals without serious psychological distress (from 3.7% in 2014 to 2.7% in 2017).

#### Smokeless Tobacco

##### Youth

In 2019, the prevalence of ever use of smokeless tobacco was 36.4% (95% CI, 30.4–42.4) among youth with a past-year alcohol use disorder, 22.3% (95% CI, 15.3–29.2) among youth with a past-year illicit drug use disorder, and 4.3% (95% CI, 3.9–4.7) among all youth (Table 2.22, Part C). The prevalence of ever use of smokeless tobacco was similar for youth with a lifetime depressive disorder (4.2%; 95% CI, 3.4–5.1) and for youth with a past-year depressive disorder (4.1%; 95% CI, 3.1–5.1) (Table 2.22, Part C).

The prevalence of current use of smokeless tobacco was 21.2% (95% CI, 18.3–24.1) among youth with a past-year alcohol use disorder, 21.0% (95% CI, 17.2–24.9) among youth with a past-year illicit drug and alcohol use disorder, 10.2% (95% CI, 4.2–16.1) among youth with a past-year illicit drug or alcohol use disorder, and 1.0% (95% CI, 0.8–1.2) among all youth (Table 2.22, Part C). The prevalence of current smokeless tobacco use was similar among youth with a lifetime depressive disorder (1.0%; 95% CI, 0.6–1.5) and youth with a past-year depressive episode (0.9%; 95% CI, 0.4–1.4) (Table 2.22, Part C).

##### Adults

In 2019, ever use of smokeless tobacco was 17.5% (95% CI, 16.4–18.6) among adults 18 years of age and older living with any past-year mental health condition. The prevalence of ever use of smokeless tobacco for adults with other mental health conditions or substance use disorders is provided in Table 2.22 Part C.

Current use of smokeless tobacco was 3.0% (95% CI, 2.5–3.4) among adults 18 years of age and older living with any past-year mental health condition. Current smokeless tobacco use did not differ between adults with (4.0%; 95% CI, 3.0–5.1) and without (3.4%; 95% CI, 3.2–3.6) past-month serious psychological distress. The prevalence of current smokeless tobacco use was 6.8% (95% CI, 5.5–8.1) among adults with a past-year alcohol use disorder, 5.8% (95% CI, 4.4–7.3) among adults with a past-year illicit drug use disorder, 9.0% (95% CI, 5.7–12.3) among adults with both past-year alcohol and illicit drug use disorders, and 3.4% (95% CI, 3.2–3.6) among adults overall (Table 2.22, Part C).

#### Cigars

##### Youth

In 2019, ever use of cigars was 34.2% (95% CI, 24.6–43.8) among youth with a past-year alcohol use disorder, 30.4% (95% CI, 23.9–36.9) among youth with a past-year illicit drug use disorder, 34.0% (95% CI, 24.8–43.3) among youth with both past-year alcohol and illicit drug use disorders, 7.3% (95% CI, 6.1–8.4) among youth with a lifetime major depressive episode, and 5.3% (95% CI, 4.8–5.8) among youth overall (Table 2.22, Part B).

Current use of cigars was 13.6% (95% CI, 6.1–21.2) among youth with a past-year alcohol use disorder, 12.7% (95% CI, 9.3–21.2) among youth with a past-year illicit drug use disorder, 21.4% (95% CI, 11.7–31.1) among youth with both past-year alcohol and illicit drug use disorders, 2.1% (95% CI, 1.5–2.8) among youth with a lifetime major depressive episode, 2.0% (95% CI, 1.3–2.8) among youth with past-year major depressive episodes, and 1.5% (95% CI, 1.2–1.7) among youth overall (Table 2.22, Part B).

##### Adults

In 2019, ever use of cigars was 39.1% (95% CI, 37.6–40.5) among adults with any past-year mental health condition and 34.1% (95% CI, 33.4–34.7) among all adults (Table 2.22, Part B). The prevalence of ever use of cigars for adults with other mental health conditions or substance use disorders is provided in Table 2.22 Part C.

Current cigar use during the past month was 6.2% (95% CI, 5.5–6.9) among adults with any past-year mental health condition and 6.7% (95% CI, 5.2–8.1) among adults with a past-year major depressive episode. The prevalence of current cigar use was higher among adults with past-month serious psychological distress (7.2%; 95% CI, 5.9–8.5) than it was among those without past-month serious psychological distress (4.5%; 95% CI, 4.2–4.7). Current cigar use during the past month was 11.7% (95% CI, 9.4–13.9) among adults with past-year alcohol use disorder, 15.0% (95% CI, 10.9–19.2) among adults with past-year illicit drug use disorder, and 24.0% (95% CI, 13.5–34.5) among adults with both past-year alcohol and illicit drug use disorder. Among all adults, 4.7% (95% CI, 4.4–4.9) reported past-month cigar use (Table 2.22, Part B).

#### Pipes

##### Youth

Ever pipe use was 13.3% (95% CI, 7.2–19.3) among youth with past-year illicit drug use disorder and 13.1% (95% CI, 7.1–19.0) among youth with past-year illicit drug or alcohol disorder. The prevalence of ever pipe use was 2.8% (95% CI, 1.8–3.7) among youth with past-year major depressive episode, 2.4% (95% CI, 1.7–3.2) among youth with a lifetime major depressive disorder, and 1.5% (95% CI, 1.2–1.7) among youth overall (Table 2.22, Part B). Current pipe use was 2.6% (95% CI, 1.1–4.1) among youth with a past-year illicit drug or alcohol disorder, 0.5% (95% CI, 0.2–0.7) among youth with a lifetime major depressive disorder, and 0.4% (95% CI, 0.2–0.5) among youth overall (Table 2.22, Part B).

##### Adults

According to the 2019 NSDUH, ever use of pipes was 15.7% (95% CI, 14.5–17.0) among adults with any past-year mental health condition (Table 2.22, Part B). The prevalence of ever use of pipes for adults with other mental health conditions or substance use disorders is provided in Table 2.22 Part B.

Current use of pipes was 1.4% (95% CI, 1.0–1.7) among adults with any past-year mental health condition and 1.2% (95% CI, 0.8–1.6) among adults with a past-year major depressive episode. The prevalence of current pipe use was higher among adults with past-month serious psychological distress (2.8%; 95% CI, 1.8–3.9) than it was among adults without past-month serious psychological distress (0.6%; 95% CI, 0.5–0.7). Current pipe use was 2.0% (95% CI, 1.3–2.7) among adults with a past-year alcohol use disorder, 3.0% (95% CI, 1.9–4.0) among adults with a past-year illicit drug use disorder, 3.1% (95% CI, 1.1–5.1) among adults with both past-year alcohol and illicit drug use disorders, and 0.8% (95% CI, 0.7–0.9) among adults overall (Table 2.22, Part B).

### Patterns of Polytobacco Use

#### Youth

According to NSDUH data from 2019, the prevalence of current polytobacco use among youth overall was 1.2% (95% CI, 1.0–1.5). The prevalence of current polytobacco use did not differ between youth with a lifetime (1.8%; 95% CI, 1.1–2.4) or past-year (1.4%; 95% CI, 0.8–2.1) major depressive episode (Table 2.22, Part A). However, the prevalence of current polytobacco use was 12.1% (95% CI, 7.1–17.1) among youth with a past-year alcohol use disorder, 11.6% (95% CI, 8.1–15.1) among youth living with a drug use disorder, and 21.5% (95% CI, 12.1–30.9) among youth with both past-year alcohol and illicit drug use disorders (Table 2.22, Part A).

#### Adults

In 2019, the prevalence of current polytobacco use among adults overall was 3.5% (95% CI, 3.3–3.7). The prevalence of current polytobacco use was 5.4% (95% CI, 4.8–6.0) among adults with any past-year mental health condition. Current polytobacco use was higher among adults with serious psychological distress during the past month (8.1%; 95% CI, 6.6–9.6) than it was among adults without serious psychological distress during the past month (3.2%; 95% CI, 3.0–3.4). The prevalence of current polytobacco use was 9.6% (95% CI, 8.0–11.0) among adults with a past-year alcohol use disorder, 14.6% (95% CI, 11.6–17.7) among adults with a past-year illicit drug use disorder, and 27.8% (95% CI, 17.3–38.3) among adults with both past-year alcohol and illicit drug use disorders (Table 2.22, Part A).

### Tobacco Use by Mental Health Condition and Sex

According to data from the 2019 NSDUH, 21.2% (95% CI, 20.6–21.7) of the U.S. adult population 18 years of age and older had a past-year mental health condition, and in that group, 26.8% (95% CI, 25.6–28.0) currently smoked cigarettes (Table 2.22, Part A). Overall, the prevalence of having a past-year mental health condition among currently smoking adults was highest in the younger age groups (i.e., 18–25 years of age and 26–34 years of age) and lowest among people 50 years of age and older (Figure 2.10). In every age group, the proportion of adults reporting a past-year mental health condition was greater among women who currently smoked than it was among men who currently smoked. For example, 48.3% (95% CI, 45.1–51.5) of young women (18–25 years of age) who smoked had a past-year mental health condition compared with 31.9% (95% CI, 28.7–35.0) of young men (18–25 years of age) who smoked.

Figure 2.10 Percentage of adults, 18 years of age and older, who had any mental health condition during the past year,^a^ a Any mental health condition during the past year was defined based on the predicted probability model developed using a subsample of NSDUH respondents who underwent a diagnostic interview via a clinical follow-up study. Refer to NSDUH 2019 Codebook for more details. among people who currently smoked cigarettes,^b^ b Current use of cigarettes was defined as having smoked part or all of a cigarette during the past 30 days. by age group and sex; National Survey on Drug Use and Health (NSDUH) 2019, United States

Within every sex and age group, except among males 26-34 years of age, the percentage of people who currently smoked and reported having any mental health condition generally decreased as people increased in age. In every age group, the proportion of adults reporting a past-year mental health condition was greater among women who currently smoked than it was among men who currently smoked.

Source: NSDUH, Substance Abuse and Mental Health Services Administration, public use data, 2019.

### Tobacco Use by Mental Health Condition and Race and Ethnicity

According to data from the 2019 NSDUH, among younger adults (18–25 and 26–34 years of age) who currently (during the past 30 days) smoked cigarettes, the proportion who reported a past-year mental health condition was higher among non-Hispanic White people than among non-Hispanic African American people (Figure 2.11). Differences in past-year mental health conditions among adults who currently smoke cigarettes by race and ethnicity were not consistent across all age groups, possibly due to sparse data on the prevalence of a past-year mental health conditions for each combination of age and racial and ethnic groups. Further, disparities in the reporting of mental health symptoms and the receipt of mental health treatment among racial and ethnic groups may reduce the validity of estimates from national surveys on this topic (Dobalian and Rivers 2008).

### Tobacco Use by Mental Health Condition and Sexual Orientation

NSDUH data from 2019 show that among adults 18–25, 26–34, and 35–49 years of age who currently smoked, the proportion who had a past-year mental health condition was higher among bisexual people compared with heterosexual people (Figure 2.12). Among bisexual people who smoke, 63.9% (95% CI, 57.5–70.3) of 18- to 25-year-olds, 61.0% (95% CI, 52.8–69.1) of 26- to 34-year-olds, and 53.0% (95% CI, 42.8–63.2) of 35- to 49-year-olds had a past-year mental health condition. In comparison, the prevalence of a past-year mental health condition among heterosexual people who smoke was 33.3% (95% CI, 30.9–35.7) for 18- to 25-year-olds, 37.0% (95% CI, 33.9–40.2) for 26- to 34-year-olds, and 29.0% (95% CI, 26.6–31.4) for 35- to 49-year-olds. Among young adults 18–25 years of age who currently smoked, the prevalence of a mental health condition differed between those who identified as lesbian or gay (51.2%; 95% CI, 39.3–63.1) and those who identified as heterosexual (33.3%; 95% CI, 30.9–35.7).

### Tobacco Use by Mental Health Condition and Socioeconomic Status

According to data from the 2019 NSDUH, adults who currently smoked and were employed part-time generally had a higher prevalence of past-year mental health conditions than adults who currently smoked and were employed full-time (Figure 2.13). However, the differences were not significant within each age group.

Among adults who currently smoked cigarettes, the association between having a past-year mental health condition and poverty status differed across age groups. Although data from the 2019 NSDUH show similar prevalence of a past-year mental health condition among 18- to 25-year-olds who currently smoke cigarettes by poverty status, the prevalence of a past-year mental health condition among those with incomes more than two times the federal poverty threshold decreases across age groups. Among people who smoke cigarettes, the proportion of people who had a past-year mental health condition was higher for those living below the poverty threshold than it was for those living with an income more than two times the federal poverty threshold in two age groups: adults 35–49 years of age and adults 50–64 years of age (Figure 2.14). Among adults 65 years of age and older who currently smoke cigarettes, the prevalence of a past-year mental health condition by poverty status was higher among those with incomes up to two times the federal poverty threshold than it was among those with incomes more than two times the federal poverty threshold. Significant differences by poverty status in the proportion of a past-year mental health condition were not observed for people who smoke in other age groups.

### Tobacco Use by Mental Health Condition and Geographic Setting

Data from the 2019 NSDUH showed that across all age groups, the proportion of people who currently smoke who had a past-year mental health condition did not differ by classification of residence (large metropolitan, small metropolitan, nonmetropolitan) (Figure 2.15).

## Tobacco Use and Cessation Behaviors by Geographic Setting

The prevalence of tobacco use across the United of tobacco control policies, the farming of tobacco, and States differs by geographic setting. Variations in the taxing other factors may contribute to disparities in tobacco of tobacco products, the presence and comprehensiveness use based on where one lives (Capehart 2004; Fallin and Glantz 2015; CDC n.d.j). This section compares the prevalence of tobacco use by state, Census region, and by urban and rural area for youth and adults. Data from the 2019 YRBS were used for estimates of tobacco use among youth, and data from the 2020 BRFSS were used for estimates of tobacco use among adults. In both datasets, estimates for product use were not consistently available for all 50 states and the District of Columbia.

Figure 2.11 Percentage of adults, 18 years of age and older, who had any mental health condition during the past year,^a^ a Any mental health condition during the past year was defined based on the predicted probability model developed using a subsample of NSDUH respondents who underwent a diagnostic interview via a clinical follow-up study. Refer to NSDUH 2019 Codebook for more details. b Current use of cigarettes was defined as having smoked part or all of a cigarette during the past 30 days. among people who currently smoked cigarettes,^b^ by age group and race and ethnicity; National Survey on Drug Use and Health (NSDUH) 2019, United States

^c^Estimates with a relative standard error ≥30% or an unweighted denominator <50 were suppressed for the following population and age groups: Hispanic (65 years of age and older), non-Hispanic African American (65 years of age and older), non-Hispanic Asian (26–34, 35–49, and 50–64 years of age and 65 years of age and older), non-Hispanic multiple race (50–64 years of age and 65 years of age and older), non-Hispanic American Indian and Alaska Native (26–34, 35–49, and 50–64 years of age and 65 years of age and older), and non-Hispanic Native Hawaiian and Other Pacific Islander (all age groups).

In 2019, within racial and ethnic groups, greater proportions of people who currently smoked cigarettes and reported having any mental health condition during the past year were observed in younger age groups (18-25 and 26-34 years of age) than in older age groups (35-49 and 50-64 years of age and 65 years of age and older). The greatest proportions of people who currently smoked and reported having a mental health condition were observed among Non-Hispanic multiple race people (53%) and non-Hispanic White people (43%) who were in the 26- to 34-year-old age group. Figure note “c” offers more details about the dataset for each age group.

Source: NSDUH, Substance Abuse and Mental Health Services Administration, public use data, 2019.

Figure 2.12 Percentage of adults, 18 years of age and older, who had any mental health condition during the past year,^a^ a Any mental health condition during the past year was defined based on the predicted probability model developed using a subsample of NSDUH respondents who underwent a diagnostic interview via a clinical follow-up study. Refer to NSDUH 2019 Codebook for more details. among people who currently smoked cigarettes,^b^ b Current use of cigarettes was defined as having smoked part or all of a cigarette during the past 30 days. by age group and sexual orientation;^c^ c Sexual orientation was determined by the following question: “Which one of the following do you consider yourself to be?” with three response options: “heterosexual, that is, straight” (n = 39,206), “lesbian or gay” (n = 880), or “bisexual” (n = 1,773). Data were ascertained only from adults 18 years of age or older. National Survey on Drug Use and Health (NSDUH) 2019, United States

^d^Estimates with a relative standard error ≥30% or an unweighted denominator <50 were suppressed for the following sexual orientation and age groups: lesbian or gay and bisexual (50–64 years of age and 65 years of age and older).

In 2019, within each of the three youngest age groups (18-25, 26-34, and 35-49 years of age), the percentage of adults who currently smoked cigarettes and reported having any mental health condition during the past year was greatest among bisexual people, followed by lesbian or gay people, and then by heterosexual people, although confidence intervals overlapped for some groups. Within each sexual orientation group, the percentage of adults who currently smoked cigarettes and reported having any mental health condition during the past year decreased with each increasing age group, except for 26- to 34-year-old people in the heterosexual group, for which the percentage increased slightly compared with people who were heterosexual in the 18- to 25-year-old age group. Figure note “d” offers more details about the dataset for two oldest age groups: 50-64 years of age and 65 years of age and older.

Source: NSDUH, Substance Abuse and Mental Health Services Administration, public use data, 2019.

### State-Specific Differences

#### Patterns of Ever and Current Use of Cigarettes

##### Youth

For the 34 states with available YRBS data, the state-specific prevalence of ever use of cigarettes (ever tried cigarettes, even one or two puffs) among U.S. high school students in 2019 (Table 2.24) was 27.9 percentage points higher in West Virginia (38.5%; 95% CI, 33.7–43.6) than Utah (10.6%; 95% CI, 8.1–13.7).

For the 42 states with available YRBS data, the prevalence of past-30-day use of cigarettes ranged from 2.2% (95% CI, 1.4–3.5) in Utah to 13.5% (95% CI, 11.1–16.3) in West Virginia (11.3 percentage points higher than Utah).

##### Adults

The state-specific prevalence of ever use of cigarettes among all adults (18 years of age and older) in 2020 ranged from 25.0% (95% CI, 23.9–26.1) in Utah to 48.5% (95% CI, 46.9–50.1) in West Virginia (Table 2.25). The prevalence of ever cigarette use among adults was 5.1 percentage points (California, 30.1%; 95% CI, 28.3–31.9) to 23.5 percentage points (West Virginia, 48.5%; 95% CI, 46.9–50.1) higher in other states than it was in Utah. The highest prevalence of ever smoking cigarettes by region was in the Midwest (41.3%; 95% CI, 40.7–41.8), followed by the South (39.8%; 95% CI, 39.2–40.4), the Northeast (37.4%; 95% CI, 36.8–38.0), and the West (34.1%; 95% CI, 33.2–35.1).

Figure 2.13 Percentage of adults, 18 years of age and older, who had any mental health condition during the past year,^a^ a Any mental health condition during the past year was defined based on the predicted probability model developed using a subsample of NSDUH respondents who underwent a diagnostic interview via a clinical follow-up study. Refer to NSDUH 2019 Codebook for more details. among people who currently smoked cigarettes,^b^ b Current use of cigarettes was defined as having smoked part or all of a cigarette during the past 30 days. by age group and employment status;^c^ c Employment status was recoded using a combination of questions about having work, number of hours working per week, and reasons for not having worked in the past week, looking for work in the past 30 days, and working at a job or business at any time during the past 12 months. Refer to NSDUH 2019 Codebook for more details. National Survey on Drug Use and Health (NSDUH) 2019, United States

^d^Estimates with a relative standard error ≥30% or an unweighted denominator <50 were suppressed for people 65 years of age and older in the following employment status groups: employed full time, employed part time, and unemployed.

In 2019, adults who currently smoked and were employed part-time generally had a higher prevalence of past-year mental health conditions than adults who currently smoked and were employed full-time. Within each employment status group (employed full-time, employed part-time, unemployed, and other [including not in labor force]), the percentage of adults who currently smoked cigarettes and reported having any mental health condition during the past year decreased with each increasing age group (18-25, 26-34, 35-49, and 50-64 years of age and 65 years of age and older), except among 26- to 34-year-olds in two employment status groups-unemployed and other (including not in the labor force)-for which respective percentages increased compared with their counterparts in the 18- to 25-year-old age group. Figure note “d” offers more details about the dataset for people in the 65-years-of-age-and-older age group.

Source: NSDUH, Substance Abuse and Mental Health Services Administration, public use data, 2019.

The state-specific prevalence of current cigarette use (defined as having smoked at least 100 cigarettes in one’s lifetime and smoking every day or some days) among all adults in 2020 ranged from 8.2% (95% CI, 7.4–8.9) in Utah to 22.6% (95% CI, 21.2–23.9) in West Virginia (Table 2.26). The prevalence of current cigarette use among adults was 0.7 percentage points (California, 8.9%; 95% CI, 7.7–10.0) to 14.4 percentage points (West Virginia, 22.6%; 95% CI, 21.2–23.9) higher in other states than it was in Utah. In four Southern states—Arkansas, Kentucky, Mississippi, and West Virginia—the prevalence of current cigarette use among adults was more than 20.0%. By region, the prevalence of current cigarette use among adults was higher in the Midwest (16.6%; 95% CI, 16.1–17.0) and the South (15.8%; 95% CI, 15.8–16.2) than it was in the Northeast (12.8%; 95% CI, 12.3–13.2) and the West (10.9%; 95% CI, 10.3–11.5) (Figure 2.16).

Among young adults (18–24 years of age) in 2020, the state-specific prevalence of ever use of cigarettes (defined as having smoked at least 100 cigarettes in one’s lifetime) ranged from 9.2% (95% CI, 6.6–11.8) in Maryland to 30.2% (95% CI, 22.1–38.2) in Wyoming (Table 2.25). The prevalence of ever cigarette use among young adults was 0.6 percentage points (New Jersey, 9.8%; 95% CI, 7.5–12.2) to 21.0 percentage points (Wyoming, 30.2%; 95% CI, 22.1–38.2) higher in other states than it was in Maryland. Ever use of cigarettes among young adults was lower in the Northeast (11.6%; 95% CI, 10.1–13.1) than it was in the Midwest (16.8%; 95% CI, 15.3–18.3) and the South (17.2%; 95% CI, 15.6–18.8); ever use of cigarettes among young adults in the West was 14.1% (95% CI, 12.0–16.1).

Among the 48 states with available data, the prevalence of current cigarette use among young adults in 2020 ranged from 4.4% (95% CI, 2.7–6.1) in New Jersey to 17.2% (95% CI, 10.5–23.9) in Wyoming (12.8 percentage points higher than New Jersey) (Table 2.26). Current cigarette use among young adults was highest in the Midwest (10.0%; 95% CI, 8.8–11.1) and lowest in the West (7.1%; 95% CI, 5.7–8.6) and the Northeast (6.5%; 95% CI, 5.4–7.7).

Figure 2.14 Percentage of adults, 18 years of age and older, who had any mental health condition during the past year,^a^ a Any mental health condition during the past year was defined based on the predicted probability model developed using a subsample of NSDUH respondents who underwent a diagnostic interview via a clinical follow-up study. Refer to NSDUH 2019 Codebook for more details. among people who currently smoked cigarettes,^b^ b Current use of cigarettes was defined as having smoked part or all of a cigarette during the past 30 days. by age group and poverty status;^c^ c Poverty status was created for each individual based on their poverty threshold (determined by their age, family size, number of children in the household, and total family income). Respondents 18 to 22 years of age currently living in a college dormitory (GQTYPE2=“C”) were set to “system missing” and do not have a valid value for this variable. Refer to NSDUH 2019 Codebook for more details (p. 569). National Survey on Drug Use and Health (NSDUH) 2019, United States

^d^Estimates with a relative standard error ≥30% or an unweighted denominator <50 were suppressed for people who were 65 years of age and older and living in poverty.

In 2019, among people who smoke cigarettes, the proportion of people who had a past-year mental health condition was higher for those living below the poverty threshold than it was for those living with an income more than two times the federal pov-erty threshold in two age groups: adults 35-49 years of age and adults 50-64 years of age. Within each poverty status group (living in poverty, income up to 2 times the federal poverty threshold, and income more than 2 times the federal poverty threshold), the percentage of adults who currently smoked cigarettes and reported having any mental health condition during the past year decreased with each increasing age group (18-25, 26-34, 35-49, and 50-64 years of age and 65 years of age and older), except for (a) 26- to 34-year-olds who were living in poverty and (b) 26- to 34-year-olds and people 65 years of age and older with income up to 2 times the federal poverty threshold, for which percentages increased compared with their respective counterparts. Figure note “d” offers more details about the dataset for people in the 65-years-of-age-and-older age group.

Source: NSDUH, Substance Abuse and Mental Health Services Administration, public use data, 2019.

#### Patterns of Frequency of Cigarette Use

##### Youth

Among the 43 states with available data, the prevalence of using cigarettes on 20 or more of the past 30 days among U.S. high school students in 2019 ranged from 0.3% (95% CI, 0.1–0.8) in Utah to 5.4% (95% CI, 3.6–7.8) in West Virginia (an absolute difference of 5.1 percentage points). The prevalence of using cigarettes daily ranged from 0.3% (95% CI, 0.1–0.8) in Utah to 4.2% (95% CI, 2.6–6.7) in West Virginia, an absolute difference of 3.9 percentage points. (Table 2.24).

##### Adults

The range in the state-specific prevalence of cigarette use in 2020 varied more for daily cigarette use (from 5.4% [95% CI, 4.8–5.9] in Utah to 18.2% [95% CI, 16.9–19.5] in West Virginia) (Table 2.27) than it did for non-daily cigarette use (from 2.8% [95% CI, 2.3–3.3] in Utah to 6.1% in Mississippi [95% CI, 5.2–7.0] and New Mexico [95% CI, 5.1–7.1]) (Table 2.28). In every state, the prevalence of daily cigarette use was higher than that of non-daily cigarette use. The prevalence of daily cigarette use among adults was 0.5 percentage points (California, 5.9%; 95% CI, 4.9–6.9) to 12.8 percentage points (West Virginia, 18.2%; 95% CI, 16.9–19.5) higher in other states than it was in Utah. The prevalence of non-daily cigarette use among adults was 0.2 percentage points (California, 3.0%; 95% CI, 2.3–3.6) to 3.3 percentage points (New Mexico, 6.1%; 95% CI, 5.1–7.1) higher in other states than it was in Utah.

By region, daily cigarette use was more prevalent in the Midwest (12.3%; 95% CI, 12.0–12.7) than it was in the other three regions (Table 2.27). Non-Daily cigarette use was more prevalent in the South (4.8%; 95% CI, 4.5–5.1) and the Midwest (4.2%; 95% CI, 4.0–4.5) than it was in the West (3.5%; 95% CI, 3.2–3.8), and it was more prevalent in the South (4.8%; 95% CI, 4.5–5.1) than it was in the Northeast (3.8%; 95% CI, 3.5–4.0) (Table 2.28).

Figure 2.15 Percentage of adults, 18 years of age and older, who had any mental health condition during the past,^a^ a Any mental health condition during the past year was defined based on the predicted probability model developed using a subsample of NSDUH respondents who underwent a diagnostic interview via a clinical follow-up study. Refer to NSDUH 2019 Codebook for more details. among people who currently smoked cigarettes,^b^ b Current use of cigarettes was defined as having smoked part or all of a cigarette during the past 30 days. by age group and metropolitan area status;^c^ c Living in metropolitan areas is recoded based on the 2013 Rural/Urban Continuum Codes. National Survey on Drug Use and Health (NSDUH) 2019, United States

In 2019, across all age groups, the proportion of people who currently smoke who had a past-year mental health condition did not differ by metropolitan status group (large metropolitan, small metropolitan, nonmetropolitan). Within each metropolitan status group, the percentage of adults who currently smoked cigarettes and reported having any mental health condition during the past year decreased with each increasing age group (18-25, 26-34, 35-49, and 50-64 years of age and 65 years of age and older), except for 26- to 34-year-olds who were living in large metropolitan areas and in small metropolitan areas, for which percentages increased slightly compared with their respective counterparts in the 18- to 25-year-old age group

Source: NSDUH, Substance Abuse and Mental Health Services Administration, public use data, 2019.

Many estimates of daily and non-daily cigarette use among young adults (18–24 years of age) in 2020 were suppressed due to a relative standard error greater than or equal to 30.0%. The estimates of daily and non-daily cigarette use among young adults in 2020 were similar across states where data were available (Tables 2.27 and 2.28). In all but 11 states, the prevalence of daily cigarette use was higher than that of non-daily use. Daily cigarette use was higher in the Midwest (6.3%; 95% CI, 5.4–7.2) than it was in the other three regions, and non-daily cigarette use was similar across all four regions.

#### Patterns of Smoking Cessation

According to data from the 2020 BRFSS, the state-specific proportion of adults making a past-year quit attempt ranged from 55.5% (95% CI, 51.3–59.6) in Kentucky to 71.0% (95% CI, 65.2–76.8) in the District of Columbia; a quit attempt was defined as a person who (a) currently smoked cigarettes and reported having stopped smoking for at least 1 day during the past 12 months because they were trying to quit smoking or (b) quit smoking during the past year. The prevalence of a past-year quit attempt among adults was 1.4 percentage points (Arkansas, 56.9%; 95% CI, 52.7–61.1) to 15.5 percentage points (District of Columbia, 71.0%; 95% CI, 65.2–76.8) higher in other states than it was in Kentucky. By region, the prevalence of a past-year quit attempt was higher in the West (66.0%; 95% CI, 63.6–68.3) and the Northeast (64.8%; 95% CI, 63.1–66.4) than it was in the Midwest (60.4%; 95% CI, 59.2–61.7); in the South, the prevalence of a past-year quit attempt was 62.9% (95% CI, 61.5–64.2) (Table 2.29).

According to data from the 2020 BRFSS, the prevalence of adults who had quit smoking for at least 6 months during the past year ranged from 3.3% (95% CI, 2.1–4.5) in Mississippi to 10.2% (95% CI, 7.5–12.9) in Utah (Table 2.30). The prevalence of quitting smoking for at least 6 months among adults was 0.1 percentage points (Alaska, 3.4%; 95% CI, 1.5–5.3) to 6.9 percentage points (Utah, 10.2%; 95% CI, 7.5–12.9) higher in other states than it was in Mississippi. By region, the prevalence of having quit smoking for at least 6 months during the past year was higher in the West (7.7%; 95% CI, 6.5–9.0) than it was in the Midwest (5.7%; 95% CI, 5.1–6.2); the prevalence of having quit for at least 6 months was otherwise similar across regions.

Table 2.24 Prevalence of cigarette use among high school students, by location; national Youth Risk Behavior Survey (YRBS) 2019, United States

Location | Ever use:^a^ % (95% CI) | Past-30-day use:^b^ % (95% CI) | ≥20-days use:^c^ % (95% CI) | Daily use:^d^ % (95% CI)
Alabama | 28.3 (24.3–32.06) | 7.1 (5.3–9.5) | 1.5 (0.9–2.6) | 1.2 (0.7–2.1)
Alaska | 27.5 (24.4–30.9) | 8.4 (6.7–10.4) | 1.6 (0.9–3.5) | 0.8 (0.3–1.8)
Arizona | 24.6 (21.4–28.0) | 5.3 (4.3–6.4) | 0.7 (0.9–1.1) | 0.4 (0.2–1.1)
Arkansas | 32.7 (27.3–38.6) | 9.7 (7.3–12.9) | 2.2 (0.9–3.6) | 1.5 (0.8–2.5)
California | 13.5 (11.5–15.7) | —^e^ | —^e^ | —^e^
Colorado | —^e^ | 5.3 (3.8–7.3) | 1.4 (0.9–2.4) | 1.1 (0.6–2.0)
Connecticut | —^e^ | 3.7 (2.4–5.7) | 1.3 (0.6–2.4) | 1.1 (0.5–2.5)
Delaware | —^e^ | —^e^ | —^e^ | —^e^
District of Columbia | —^e^ | —^e^ | —^e^ | —^e^
Florida | 16.8 (15.3–18.4) | 4.8 (4.1–5.7) | 1.3 (1.0–1.7) | 1.1 (0.8–1.4)
Georgia | 18.6 (15.5–22.2) | 4.0 (3.0–5.4) | 0.9 (0.5–1.6) | 0.8 (0.4–1.4)
Hawai‘i | 17.8 (15.9–19.8) | 5.3 (4.2–6.6) | 1.2 (0.8–1.9) | 0.9 (0.6–1.4)
Idaho | 22.2 (19.2–25.4) | 5.3 (4.1–6.9) | 0.8 (0.3–2.1) | 0.5 (0.2–1.3)
Illinois | 19.8 (17.2–22.6) | 4.7 (3.6–6.1) | 1.2 (0.7–2.2) | 0.9 (0.5–1.4)
Indiana | —^e^ | —^e^ | —^e^ | —^e^
Iowa | 25.0 (21.1–29.2) | 6.7 (5.2–8.6) | 1.6 (0.8–3.0) | 1.2 (0.5–2.6)
Kansas | 24.8 (22.3–27.6) | 5.8 (4.4–7.7) | 1.6 (1–2.5) | 1.3 (0.8–2.1)
Kentucky | 30.6 (26.4–35.1) | 8.9 (6.7–11.8) | 3.0 (1.8–4.7) | 2.2 (1.3–3.6)
Louisiana | 31.0 (25.5–37.1) | 8.4 (5.8–12.2) | 2.3 (1.3–4.0) | 1.6 (0.8–3.1)
Maine | 22.9 (21.1–24.9) | 6.8 (5.9–7.9) | 1.8 (1.4–2.3) | 1.3 (1.0–1.8)
Maryland | 17.7 (15.0–20.8) | 5.0 (4.5–5.4) | 1.1 (0.9–1.2) | 0.8 (0.7–0.9)
Massachusetts | 21.1 (18.4–24.2) | 5.0 (3.8–6.6) | 0.6 (0.3–1.1) | 0.4 (0.2–0.9)
Michigan | —^e^ | 4.5 (2.9–7.0) | 1.0 (0.4–2.7) | 0.6 (0.2–1.3)
Minnesota | —^e^ | —^e^ | —^e^ | —^e^
Mississippi | 30.6 (27.2–34.2) | 6.6 (4.9–8.8) | 1.4 (0.9–2.2) | 1.0 (0.6–1.6)
Missouri | —^e^ | 6.5 (4.8–8.9) | 1.1 (0.6–2.1) | 0.9 (0.5–1.7)
Montana | 31.0 (28.6–33.6) | 7.7 (6.5–9.0) | 1.5 (1.1–2.1) | 1.2 (0.8–1.7)
Nebraska | 22.8 (19.7–26.2) | 4.2 (3.0–5.8) | 1.2 (0.6–2.4) | 0.9 (0.4–1.9)
Nevada | 17.5 (14.6–20.8) | 3.6 (2.7–5.0) | 0.7 (0.4–1.1) | 0.4 (0.2–0.6)
New Hampshire | —^e^ | 5.5 (5.1–6.0) | 1.7 (1.4–1.9) | 1.4 (1.1–1.6)
New Jersey | —^e^ | 3.8 (2.6–5.5) | 0.7 (0.3–1.8) | 0.7 (0.3–1.8)
New Mexico | 30.3 (27.5–33.3) | 8.9 (7.7–10.3) | 1.6 (1.1–2.1) | 0.9 (0.7–1.3)
New York | 14.7 (12.9–16.6) | 4.2 (3.4–5.2) | 0.8 (0.6–1.2) | 0.6 (0.4–0.9)
North Carolina | —^e^ | 8.3 (6.5–10.6) | 1.9 (1.0–3.7) | 1.5 (0.8–3.0)
North Dakota | 29.3 (26.4–32.4) | 8.3 (6.6–10.5) | 2.1 (1.3–3.3) | 1.4 (0.8–2.4)
Ohio | 21.5 (16.3–27.8) | 4.9 (3.1–7.5) | 0.5 (0.2–1.1) | 0.4 (0.2–1.0)
Oklahoma | 34.1 (30.2–38.2) | 9.1 (6.9–11.9) | 2.4 (1.5–3.7) | 1.8 (1.2–2.6)
Oregon | —^e^ | —^e^ | —^e^ | —^e^
Pennsylvania | 21.8 (19.2–24.7) | 6.6 (5.1–8.6) | 2.1 (1.4–3.2) | 1.6 (1.0–2.6)
Rhode Island | 17.5 (15.4–19.7) | 4.2 (3.2–5.5) | 1.6 (0.9–3.0) | 1.6 (0.9–3.0)
South Carolina | 23.1 (18.7–28.1) | 5.9 (4.7–7.4) | 1.8 (1.0–3.0) | 1.5 (0.8–2.8)
South Dakota | 31.4 (25.2–38.2) | 12.0 (7.7–18.2) | 3.4 (2.0–5.8) | 2.2 (1.2–4.0)
Tennessee | 29.2 (24.7–34.1) | 7.1 (5.1–9.9) | 1.9 (1.0–3.5) | 1.5 (0.8–2.9)
Texas | —^e^ | 4.9 (3.8–6.3) | 0.7 (0.3–1.4) | 0.6 (0.3–1.4)
Utah | 10.6 (8.1–13.7) | 2.2 (1.4–3.5) | 0.3 (0.1–0.8) | 0.3 (0.1–0.8)
Vermont | —^e^ | —^e^ | 2.0 (1.8–2.2) | 1.6 (1.4–1.8)
Virginia | —^e^ | 5.5 (4.6–6.5) | 1.3 (0.9–1.9) | 1.1 (0.7–1.6)
Washington | —^e^ | —^e^ | —^e^ | —^e^
West Virginia | 38.5 (33.7–43.6) | 13.5 (11.1–16.3) | 5.4 (3.6–7.8) | 4.2 (2.6–6.7)
Wisconsin | 19.1 (15.1–23.9) | 5.7 (4.0–8.0) | 0.7 (0.3–1.5) | 0.6 (0.2–1.5)
Wyoming | —^e^ | —^e^ | —^e^ | —^e^

Source: CDC (n.d.a).

Notes:CI = confidence interval.

a Even one or two puffs.

b On at least 1 day during the 30 days before the survey.

c On 20 or more days during the 30 days before the survey.

d On all 30 days during the 30 days before the survey.

e The number of respondents within the subgroup did not meet the minimum reporting threshold or data were not available.

Table 2.25 Prevalence of ever use of cigarettes^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 43.4 (41.6–45.2) | 21.9 (16.1–27.7) | 43.5 (40.1–46.9) | 47.6 (44.7–50.5) | 48.6 (45.5–51.7)
Alaska | 43.9 (41.4–46.4) | 14.7 (8.7–20.6) | 47.5 (43.0–52.0) | 49.4 (45.4–53.5) | 46.9 (42.3–51.4)
Arizona | 39.2 (37.8–40.6) | 14.7 (11.3–18.1) | 37.6 (35.0–40.2) | 42.3 (40.0–44.7) | 49.9 (47.3–52.5)
Arkansas | 44.8 (42.8–46.8) | 19.8 (13.2–26.4) | 46.2 (42.2–50.2) | 48.8 (45.8–51.9) | 51.1 (48.5–53.7)
California | 30.1 (28.3–31.9) | 12.5 (8.6–16.4) | 26.5 (23.6–29.3) | 32.7 (29.2–36.1) | 43.8 (39.7–48.0)
Colorado | 38.6 (37.5–39.8) | 16.6 (13.6–19.6) | 40.9 (38.7–43.0) | 39.6 (37.7–41.5) | 46.6 (44.4–48.8)
Connecticut | 37.5 (35.9–39.1) | 10.1 (6.6–13.7) | 34.9 (31.8–37.9) | 41.0 (38.5–43.5) | 50.3 (47.5–53.1)
Delaware | 41.3 (39.1–43.5) | 13.0 (7.6–18.5) | 41.3 (36.9–45.6) | 43.5 (40.0–46.9) | 50.5 (46.6–54.4)
District of Columbia | 30.4 (28.3–32.4) | 13.6 (6.8–20.4) | 26.8 (23.6–30.0) | 37.6 (34.1–41.1) | 41.5 (37.7–45.3)
Florida | 41.7 (39.8–43.7) | 16.3 (11.7–20.9) | 38.7 (34.8–42.6) | 46.1 (42.6–49.6) | 49.9 (47.0–52.8)
Georgia | 37.0 (35.4–38.7) | 14.5 (10.2–18.8) | 36.7 (33.5–39.9) | 40.1 (37.3–42.9) | 47.5 (44.9–50.2)
Hawai‘i | 37.4 (35.8–38.9) | 23.0 (18.3–27.7) | 35.4 (32.6–38.2) | 37.6 (35.0–40.2) | 46.0 (43.1–48.9)
Idaho | 37.8 (36.1–39.6) | 18.4 (14.0–22.8) | 36.4 (33.1–39.7) | 43.0 (39.8–46.2) | 44.0 (40.8–47.2)
Illinois | 35.1 (33.1–37.1) | 15.1 (9.6–20.7) | 30.9 (27.5–34.4) | 39.8 (36.0–43.6) | 45.8 (41.9–49.6)
Indiana | 43.2 (41.9–44.5) | 17.4 (13.6–21.2) | 46.0 (43.4–48.6) | 48.8 (46.8–50.8) | 46.3 (44.1–48.5)
Iowa | 39.9 (38.7–41.1) | 16.0 (13.0–19.0) | 43.9 (41.6–46.1) | 43.2 (41.3–45.2) | 43.9 (41.8–46.0)
Kansas | 41.1 (39.9–42.4) | 19.1 (15.5–22.6) | 41.5 (39.2–43.9) | 47.0 (44.9–49.1) | 46.3 (44.3–48.3)
Kentucky | 47.9 (45.9–50.0) | 21.3 (15.2–27.4) | 50.5 (46.7–54.3) | 52.6 (49.3–55.9) | 52.2 (48.6–55.8)
Louisiana | 41.7 (39.8–13.6) | 22.0 (16.1–28.0) | 40.8 (37.1–44.4) | 46.7 (43.7–49.8) | 46.9 (43.6–50.3)
Maine | 46.5 (45.0–18.0) | 18.7 (12.9–24.4) | 50.6 (47.4–53.8) | 46.3 (44.0–48.7) | 53.1 (51.0–55.1)
Maryland | 33.0 (31.9–34.1) | 9.2 (6.6–11.8) | 30.6 (28.4–32.8) | 35.3 (33.5–37.1) | 46.2 (44.1–48.2)
Massachusetts | 35.6 (34.1–37.1) | 10.8 (7.6–14.0) | 31.5 (28.6–34.3) | 39.2 (36.6–41.8) | 50.1 (47.1–53.2)
Michigan | 45.6 (44.1–47.2) | 18.6 (14.1–23.0) | 47.0 (43.9–50.0) | 49.8 (47.3–52.3) | 52.2 (49.7–54.7)
Minnesota | 39.5 (38.6–40.4) | 13.2 (10.8–15.6) | 39.9 (38.2–41.7) | 42.6 (41.1–44.2) | 48.2 (46.3–50.0)
Mississippi | 40.5 (38.9–42.2) | 17.9 (12.7–23.2) | 41.8 (38.6–44.9) | 45.2 (42.6–47.8) | 43.2 (40.7–15.7)
Missouri | 43.1 (41.7–44.5) | 17.8 (14.2–21.3) | 44.0 (41.4–46.7) | 48.3 (46.0–50.6) | 47.9 (45.5–50.3)
Montana | 43.7 (42.2–45.3) | 23.7 (19.2–28.3) | 45.6 (42.5–48.6) | 44.8 (42.3–17.4) | 49.4 (46.9–51.9)
Nebraska | 37.8 (36.6–39.0) | 16.0 (13.0–19.0) | 38.7 (36.3–41.1) | 42.0 (40.0–44.1) | 43.5 (41.6–15.4)
Nevada | 39.4 (36.7–42.2) | 14.6 (9.0–20.2) | 30.9 (26.3–35.5) | 43.3 (38.5–18.0) | 59.8 (54.3–65.3)
New Hampshire | 43.2 (41.4–44.9) | 14.5 (9.1–19.9) | 44.2 (40.3–48.2) | 45.1 (42.6–17.6) | 52.8 (50.4–55.3)
New Jersey | 35.1 (33.9–36.3) | 9.8 (7.5–12.2) | 31.9 (29.7–34.1) | 38.7 (36.8–10.7) | 47.2 (44.7–49.7)
New Mexico | 41.3 (39.3–43.2) | 17.0 (11.8–22.2) | 44.1 (40.2–18.0) | 41.4 (38.2–14.7) | 49.5 (46.5–52.6)
New York | 34.9 (33.8–36.0) | 10.9 (8.3–13.5) | 30.6 (28.6–32.6) | 39.7 (37.8–11.5) | 47.0 (44.8–49.2)
North Carolina | 40.3 (38.7–41.9) | 17.5 (13.3–21.6) | 37.9 (35.0–10.8) | 44.4 (41.7–47.1) | 50.1 (47.0–53.1)
North Dakota | 40.2 (38.1–42.2) | 20.9 (14.7–27.2) | 42.7 (38.7–46.8) | 40.3 (37.1–43.5) | 48.0 (45.3–50.8)
Ohio | 43.3 (42.1–44.5) | 17.9 (14.7–21.2) | 45.2 (42.8–17.6) | 46.7 (44.9–48.6) | 49.4 (47.3–51.4)
Oklahoma | 44.4 (42.6–46.2) | 20.2 (15.2–25.1) | 45.8 (42.4–49.2) | 48.2 (45.3–51.2) | 51.2 (48.3–54.1)
Oregon | 40.4 (38.8–42.0) | 18.2 (13.9–22.5) | 37.2 (34.5–39.9) | 44.7 (42.0–47.4) | 49.6 (46.4–52.8)
Pennsylvania | 41.6 (39.8–13.4) | 13.4 (9.2–17.6) | 42.1 (38.8–45.5) | 44.6 (41.7–47.4) | 50.1 (46.6–53.6)
Rhode Island | 38.2 (36.3–10.2) | 10.4 (5.2–15.6) | 34.6 (30.7–38.6) | 44.0 (41.0–46.9) | 50.0 (46.9–53.2)
South Carolina | 43.4 (41.4–45.5) | 18.4 (13.0–23.8) | 42.2 (38.0–46.4) | 46.7 (43.4–50.0) | 52.9 (49.7–56.1)
South Dakota | 43.5 (40.8–46.2) | 20.4 (13.3–27.5) | 49.2 (43.7–54.8) | 43.9 (39.6–48.2) | 47.5 (43.6–51.4)
Tennessee | 44.7 (42.7–46.8) | 20.2 (13.4–27.1) | 43.8 (40.1–47.6) | 49.6 (46.2–52.9) | 51.7 (48.0–55.3)
Texas | 35.5 (33.7–37.3) | 17.1 (12.5–21.7) | 35.7 (32.6–38.8) | 37.9 (34.8–40.9) | 44.4 (40.6–18.2)
Utah | 25.0 (23.9–26.1) | 11.6 (9.3–13.9) | 27.1 (25.2–29.0) | 28.8 (26.7–30.8) | 26.9 (24.8–29.0)
Vermont | 42.5 (40.6–44.3) | 19.6 (12.5–26.7) | 43.7 (39.9–47.4) | 45.6 (43.0–48.2) | 48.9 (46.0–51.8)
Virginia | 36.9 (35.5–38.2) | 15.5 (12.1–18.9) | 35.4 (32.8–38.0) | 40.6 (38.3–42.9) | 46.3 (43.9–18.7)
Washington | 37.5 (36.3–38.6) | 12.4 (9.9–15.0) | 36.1 (34.1–38.2) | 39.5 (37.6–11.3) | 49.2 (47.1–51.4)
West Virginia | 48.5 (46.9–50.1) | 19.4 (13.8–25.1) | 53.3 (50.0–56.5) | 51.8 (49.3–54.3) | 51.3 (48.8–53.8)
Wisconsin | 42.1 (40.1–44.0) | 14.8 (9.2–20.3) | 44.2 (40.2–48.1) | 45.3 (42.2–18.4) | 48.9 (45.6–52.1)
Wyoming | 44.3 (42.2–46.4) | 30.2 (22.1–38.2) | 46.7 (42.6–50.8) | 43.4 (40.1–16.8) | 49.7 (46.8–52.7)
Region
Northeast | 37.4 (36.8–38.0) | 11.6 (10.1–13.1) | 34.7 (33.6–35.9) | 41.1 (40.1–12.2) | 48.8 (47.5–50.1)
Midwest | 41.3 (40.7–41.8) | 16.8 (15.3–18.3) | 41.7 (40.7–42.8) | 45.4 (44.5–16.4) | 48.0 (47.0–49.0)
South | 39.8 (39.2–40.4) | 17.2 (15.6–18.8) | 38.8 (37.7–39.9) | 43.4 (42.4–44.5) | 48.4 (47.3–49.5)
West | 34.1 (33.2–35.1) | 14.1 (12.0–16.1) | 31.7 (30.1–33.2) | 36.7 (34.9–38.5) | 46.2 (44.2–48.2)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes:CI = confidence interval.

a Ever use of cigarettes was defined as having smoked at least 100 cigarettes in one’s lifetime.

Table 2.26 Prevalence of current use of cigarettes^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 18.5 (17.0–19.9) | 11.1 (6.7–15.5) | 24.3 (21.2–27.3) | 21.5 (18.9–24.0) | 9.9 (8.1–11.7)
Alaska | 18.0 (16.0–20.0) | 10.1 (5.0–15.2) | 23.7 (19.9–27.6) | 19.8 (16.6–23.0) | 8.1 (5.5–10.8)
Arizona | 13.1 (12.2–14.1) | 6.9 (4.5–9.2) | 16.7 (14.7–18.7) | 15.1 (13.5–16.8) | 8.7 (7.4–10.1)
Arkansas | 20.5 (18.8–22.1) | 12.9 (7.4–18.4) | 25.7 (22.2–29.2) | 24.7 (21.9–27.5) | 11.7 (9.9–13.4)
California | 8.9 (7.7–10.0) | 6.5 (3.7–9.2) | 10.5 (8.4–12.5) | 10.1 (7.9–12.4) | 5.4 (3.7–7.1)
Colorado | 12.4 (11.6–13.2) | 8.0 (5.9–10.1) | 15.8 (14.3–17.4) | 13.1 (11.8–14.4) | 7.3 (6.2–8.5)
Connecticut | 11.8 (10.8–12.9) | 6.7 (3.9–9.4) | 16.7 (14.3–19.1) | 12.8 (11.0–14.6) | 7.0 (5.4–8.6)
Delaware | 15.1 (13.5–16.8) | 7.3 (3.0–11.5) | 20.9 (17.3–24.6) | 16.5 (14.0–19.1) | 9.8 (7.1–12.5)
District of Columbia | 11.3 (9.8–12.9) | —^b^ | 10.9 (8.5–13.3) | 15.6 (13.0–18.2) | 8.8 (6.6–11.1)
Florida | 14.7 (13.2–16.2) | 5.9 (3.6–8.3) | 19.2 (15.9–22.6) | 18.3 (15.6–21.1) | 8.6 (7.0–10.2)
Georgia | 15.8 (14.5–17.1) | 8.0 (4.9–11.1) | 19.5 (16.9–22.2) | 18.8 (16.5–21.1) | 9.4 (8.0–10.9)
Hawai‘i | 11.6 (10.6–12.7) | 11.4 (7.6–15.3) | 14.5 (12.4–16.5) | 11.8 (10.0–13.6) | 7.6 (6.0–9.2)
Idaho | 13.6 (12.4–14.9) | 9.9 (6.5–13.4) | 17.3 (14.8–19.8) | 15.9 (13.6–18.3) | 7.2 (5.7–8.7)
Illinois | 12.7 (11.3–14.1) | 9.7 (5.6–13.7) | 13.7 (11.3–16.1) | 14.8 (12.1–17.6) | 9.6 (7.1–12.1)
Indiana | 19.4 (18.3–20.5) | 11.4 (8.2–14.7) | 24.4 (22.1–26.7) | 23.2 (21.5–25.0) | 11.2 (9.8–12.6)
Iowa | 15.8 (14.8–16.7) | 10.0 (7.5–12.6) | 22.2 (20.3–24.2) | 17.7 (16.1–19.2) | 7.7 (6.6–8.8)
Kansas | 16.6 (15.6–17.6) | 10.5 (7.6–13.4) | 20.1 (18.1–22.1) | 20.7 (18.9–22.4) | 9.4 (8.1–10.7)
Kentucky | 21.4 (19.7–23.1) | 12.3 (7.1–17.5) | 26.7 (23.2–30.1) | 25.2 (22.4–28.1) | 13.0 (10.6–15.4)
Louisiana | 18.3 (16.8–19.8) | 11.9 (7.1–16.8) | 22.0 (18.9–25.1) | 22.1 (19.5–24.7) | 10.3 (8.4–12.3)
Maine | 16.5 (15.3–17.7) | 12.3 (7.2–17.5) | 24.4 (21.5–27.2) | 17.3 (15.5–19.1) | 8.9 (7.6–10.1)
Maryland | 10.9 (10.1–11.7) | 5.2 (3.2–7.2) | 14.0 (12.3–15.7) | 12.2 (10.9–13.4) | 7.0 (6.0–8.1)
Massachusetts | 11.1 (10.0–12.2) | 6.8 (4.1–9.6) | 13.5 (11.2–15.7) | 12.8 (11.0–14.6) | 7.4 (5.6–9.3)
Michigan | 18.4 (17.1–19.7) | 10.8 (7.5–14.1) | 23.5 (20.8–26.1) | 22.4 (20.1–24.7) | 9.9 (8.4–11.5)
Minnesota | 13.8 (13.2–14.5) | 7.8 (5.9–9.7) | 18.2 (16.8–19.6) | 15.2 (14.1–16.3) | 8.5 (7.4–9.5)
Mississippi | 20.1 (18.7–21.5) | 11.0 (6.6–15.5) | 25.9 (23.0–28.8) | 23.4 (21.1–25.6) | 10.7 (9.0–12.4)
Missouri | 17.8 (16.7–18.9) | 9.9 (7.0–12.7) | 22.8 (20.5–25.1) | 20.5 (18.6–22.4) | 11.1 (9.5–12.7)
Montana | 16.4 (15.2–17.6) | 12.3 (8.7–15.8) | 23.4 (20.6–26.1) | 15.9 (14.0–17.8) | 10.2 (8.6–11.9)
Nebraska | 13.9 (13.1–14.8) | 7.9 (5.7–10.1) | 17.7 (15.9–19.5) | 17.2 (15.6–18.8) | 7.2 (6.2–8.2)
Nevada | 14.2 (12.4–16.1) | —^b^ | 14.9 (11.6–18.2) | 17.3 (13.8–20.8) | 13.4 (10.0–16.9)
New Hampshire | 13.9 (12.6–15.2) | 9.6 (4.9–14.3) | 18.9 (15.8–22.0) | 14.8 (13.0–16.6) | 8.6 (6.9–10.4)
New Jersey | 10.8 (10.0–11.6) | 4.4 (2.7–6.1) | 13.8 (12.1–15.5) | 12.7 (11.4–14.1) | 6.7 (5.6–7.9)
New Mexico | 16.1 (14.5–17.6) | 9.7 (5.8–13.6) | 22.0 (18.5–25.4) | 16.6 (14.1–19.1) | 10.7 (8.6–12.8)
New York | 12.0 (11.2–12.8) | 5.5 (3.6–7.3) | 14.5 (12.8–16.1) | 15.3 (13.9–16.7) | 6.8 (5.8–7.8)
North Carolina | 16.5 (15.3–17.8) | 8.4 (5.5–11.4) | 20.3 (17.8–22.8) | 19.8 (17.5–22.0) | 10.5 (8.6–12.3)
North Dakota | 17.4 (15.6–19.1) | 16.9 (11.1–22.8) | 21.8 (18.2–25.3) | 17.8 (15.2–20.4) | 9.8 (8.1–11.5)
Ohio | 19.3 (18.3–20.2) | 10.5 (8.0–12.9) | 25.2 (23.1–27.3) | 22.6 (21.1–24.2) | 11.2 (9.9–12.5)
Oklahoma | 19.1 (17.6–20.6) | 11.1 (7.1–15.0) | 23.2 (20.2–26.2) | 22.6 (20.1–25.1) | 12.6 (10.6–14.6)
Oregon | 13.3 (12.3–14.4) | 11.2 (7.6–14.8) | 14.8 (12.8–16.8) | 15.9 (14.0–17.8) | 8.9 (7.0–10.8)
Pennsylvania | 15.8 (14.5–17.1) | 8.0 (4.5–11.6) | 21.3 (18.5–24.0) | 17.4 (15.3–19.6) | 10.2 (8.0–12.4)
Rhode Island | 13.5 (12.0–14.9) | —^b^ | 16.8 (13.7–19.9) | 16.2 (13.8–18.5) | 8.4 (6.6–10.2)
South Carolina | 18.1 (16.5–19.8) | 12.2 (7.6–16.8) | 21.4 (18.0–24.9) | 23.1 (20.2–26.1) | 10.0 (7.8–12.1)
South Dakota | 17.8 (15.5–20.1) | 11.9 (6.1–17.6) | 26.1 (20.8–31.4) | 17.6 (14.2–20.9) | 9.5 (7.2–11.8)
Tennessee | 19.5 (17.8–21.2) | 13.4 (7.3–19.5) | 21.1 (18.1–24.0) | 23.8 (20.8–26.8) | 14.0 (11.3–16.8)
Texas | 13.2 (12.0–14.4) | 8.6 (5.7–11.4) | 15.2 (12.9–17.6) | 15.7 (13.5–17.9) | 8.2 (6.3–10.2)
Utah | 8.2 (7.4–8.9) | 4.9 (3.3–6.4) | 10.0 (8.6–11.4) | 10.2 (8.7–11.6) | 3.4 (2.6–4.3)
Vermont | 13.3 (11.9–14.6) | 10.7 (5.0–16.3) | 18.8 (15.8–21.7) | 14.4 (12.5–16.3) | 7.1 (5.4–8.7)
Virginia | 13.6 (12.7–14.6) | 8.4 (5.7–11.0) | 16.5 (14.6–18.5) | 15.5 (13.8–17.1) | 9.4 (7.8–11.1)
Washington | 11.5 (10.7–12.2) | 6.1 (4.2–8.0) | 13.7 (12.3–15.2) | 13.3 (12.0–14.6) | 7.9 (6.7–9.2)
West Virginia | 22.6 (21.2–23.9) | 8.5 (4.7–12.4) | 31.2 (28.2–34.3) | 27.5 (25.2–29.7) | 12.7 (11.0–14.4)
Wisconsin | 15.5 (14.0–17.0) | 7.4 (3.5–11.4) | 19.7 (16.4–23.1) | 18.3 (15.8–20.8) | 10.0 (7.9–12.1)
Wyoming | 18.5 (16.7–20.2) | 17.2 (10.5–23.9) | 24.6 (21.1–28.2) | 18.3 (15.7–21.0) | 10.5 (8.7–12.4)
Region
Northeast | 12.8 (12.3–13.2) | 6.5 (5.4–7.7) | 16.3 (15.4–17.3) | 14.9 (14.2–15.7) | 7.9 (7.2–8.6)
Midwest | 16.6 (16.1–17.0) | 10.0 (8.8–11.1) | 20.8 (19.9–21.6) | 19.5 (18.7–20.2) | 10.0 (9.4–10.6)
South | 15.8 (15.3–16.2) | 8.9 (7.9–10.0) | 19.2 (18.3–20.1) | 18.9 (18.1–19.7) | 9.7 (9.1–10.3)
West | 10.9 (10.3–11.5) | 7.1 (5.7–8.6) | 13.0 (11.9–14.1) | 12.3 (11.1–13.5) | 7.1 (6.2–7.9)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes:CI = confidence interval.

a Current use of cigarettes was defined as having smoked at least 100 cigarettes in one’s lifetime and smoking every day or some days at the time of the survey.

b Estimate is not presented because of a relative standard error >30%. Relative standard error is equal to the standard error of a survey

The proportion of adults who smoked cigarettes and made a quit attempt during the past year was generally higher among young adults (18–24 years of age) than it was among adults in older age groups (Table 2.29). According to data from the 2020 BRFSS, in every state but one (North Dakota), at least 60% of young adults who smoked cigarettes had attempted to quit during the past year, as evidenced by having stopped smoking for 1 day or longer (Table 2.29); estimates ranged from 53.6% (95% CI, 35.7–71.5) in North Dakota to 97.5% (95% CI, 94.2–100.0) in Alabama. Estimates of a past-year quit attempt among young adults who smoke were similar by region, ranging from 74.1% (95% CI, 69.8–78.4) in the Midwest to 82.9% (95% CI, 78.1–87.7) in the Northeast.

Many estimates of successful quitting for at least 6 months during the past year among young adults in 2020 were suppressed due to a relative standard error greater than or equal to 30.0% (Table 2.30). By region, successful quitting for at least 6 months during the past year among young adults was similar by region, ranging from 7.6% (95% CI, 4.4–10.8) in the Northeast to 10.4% (95% CI, 7.5–13.3) in the South (Table 2.30).

#### Patterns of the Use of Other Tobacco Products

##### E-Cigarettes

Youth. For the 42 states with available data, ever and past-30-day use of e-cigarettes among U.S. high school students in 2019 was lowest in Utah (ever use: 30.5%; 95% CI, 26.0–35.5; past-30-day use: 9.7%; 95% CI, 7.3–12.6) and highest in West Virginia (ever use: 62.4%; 95% CI, 57.6–67.0; past-30-day use: 35.7%; 95% CI, 30.7–41.1) (Table 2.31). The prevalence of ever e cigarette use was 9.2 percentage points (Maryland, 39.7%; 95% CI, 38.6–40.9) to 31.9 percentage points (West Virginia, 62.4%; 95% CI, 57.6–67.0) higher in other states (with available data) than it was in Utah. The prevalence of current e-cigarette use was 7.3 percentage points (Georgia, 17.0%; 95% CI, 13.9–20.6) to 26 percentage points (West Virginia, 35.7%; 95% CI, 30.7–41.1) higher in other states (with available data) than it was in Utah. Ten states (Hawaii, Maine, Massachusetts, Montana, New Hampshire, New Mexico, North Carolina, North Dakota, Rhode Island, and West Virginia) had a prevalence of past-30-day e-cigarette use above 30%.

Figure 2.16 Prevalence of current use of cigarettes^a^ a Current use of cigarettes was defined as having smoked at least 100 cigarettes in one’s lifetime and smoking “every day” or “some days” at the time of the survey. among adults, 18 years of age and older, by region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Notes: CI = confidence interval.

In 2020, the prevalence of current cigarette use among adults was higher in the Midwest (16.6%) and the South (15.8%) than it was in the Northeast (12.8%) and the West (10.9%).

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

For the 43 states with available data, frequent use of e-cigarettes (use on 20 or more days during the past 30 days) among U.S. high school students ranged from 3.3% (95% CI, 2.3–4.7) in Utah to 16.7% (95% CI, 12.3–22.3) in West Virginia. Daily use of e-cigarettes ranged from 2.4% in both California (2.4%; 95% CI, 1.4–4.1) and Utah (2.4%; 95% CI, 1.6–3.8) to 12.6% (95% CI, 9.2–17.0) in West Virginia. The prevalence of frequent e-cigarette use was 0.3 percentage points (California, 3.6%; 95% CI, 2.4–5.4) to 13.4 percentage points (West Virginia, 16.7%; 95% CI, 12.3–22.3) higher in other states (with available data) than it was in Utah. Furthermore, the prevalence of daily e-cigarette use was 0.9 percentage points (Nevada, 3.3%; 95% CI, 1.9–5.5) to 10.2 percentage points (West Virginia, 12.6%; 95% CI, 9.2–17.0) higher in other states (with available data) than it was in Utah and California.

Adults. In 2020, eight states and the District of Columbia did not field the BRFSS optional module for e-cigarettes. In the states with available data, the state-specific prevalence of ever use of e-cigarettes (ever used an e-cigarette or other electronic vaping product, even just one time) among all adults in 2020 ranged from 12.2% (95% CI, 10.6–13.8) in Illinois to 30.4% (95% CI, 28.3–32.4) in Kentucky (Table 2.32). The prevalence of ever e-cigarette use was 6.9 percentage points (Massachusetts, 19.1%; 95% CI, 17.2–21.0) to 18.2 percentage points (Kentucky, 30.4%; 95% CI, 28.3–32.4) higher in other states (with available data) than it was in Illinois. By region, ever use of e-cigarettes among adults was lower in the Northeast (21.4%; 95% CI, 20.7–22.0) than it was in the Midwest (23.8%; 95% CI, 23.2–24.4), South (24.3%; 95% CI, 23.7–25.0) and the West (25.5%; 95% CI, 24.9–26.0).

Table 2.27 Prevalence of daily use of cigarettes^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United State

Location and region | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 13.2 (12.0–14.5) | 6.0 (2.9–9.1) | 17.0 (14.4–19.6) | 16.0 (13.7–18.4) | 7.7 (6.1–9.3)
Alaska | 13.5 (11.7–15.3) | —^b^ | 17.5 (14.0–20.9) | 14.8 (11.9–17.7) | 7.1 (4.5–9.7)
Arizona | 9.0 (8.2–9.8) | 2.9 (1.3–4.5) | 11.0 (9.3–12.7) | 11.3 (9.9–12.8) | 6.4 (5.2–7.6)
Arkansas | 15.0 (13.6–16.5) | —^b^ | 19.4 (16.2–22.5) | 18.3 (15.8–20.8) | 8.7 (7.1–10.3)
California | 5.9 (4.9–6.9) | —^b^ | 6.4 (4.6–8.2) | 7.1 (5.2–9.1) | 4.5 (3.0–6.0)
Colorado | 8.4 (7.8–9.1) | 4.6 (3.0–6.1) | 10.8 (9.4–12.1) | 9.3 (8.2–10.5) | 4.9 (4.0–5.9)
Connecticut | 8.2 (7.3–9.1) | 4.0 (1.9–6.2) | 11.5 (9.4–13.6) | 9.0 (7.5–10.4) | 5.1 (3.7–6.5)
Delaware | 10.6 (9.2–12.0) | —^b^ | 15.1 (11.9–18.4) | 12.1 (10.0–14.2) | 6.3 (4.1–8.6)
District of Columbia | 6.1 (5.0–7.2) | —^b^ | 5.8 (4.1–7.5) | 8.6 (6.6–10.6) | 5.4 (3.6–7.3)
Florida | 9.4 (8.4–10.4) | 2.3 (1.1–3.5) | 11.8 (9.5–14.0) | 11.6 (9.7–13.6) | 6.9 (5.4–8.3)
Georgia | 10.8 (9.7–11.9) | 4.4 (1.9–6.8) | 13.2 (10.9–15.5) | 13.7 (11.6–15.8) | 6.1 (4.9–7.3)
Hawai‘i | 8.0 (7.1–8.9) | 4.8 (2.2–7.3) | 9.8 (8.0–11.5) | 8.9 (7.3–10.5) | 5.8 (4.3–7.2)
Idaho | 9.7 (8.6–10.7) | 5.0 (2.3–7.6) | 11.6 (9.5–13.7) | 12.4 (10.4–14.5) | 5.7 (4.3–7.1)
Illinois | 9.5 (8.3–10.7) | 6.5 (3.3–9.7) | 9.2 (7.2–11.1) | 12.1 (9.6–14.5) | 7.8 (5.5–10.2)
Indiana | 14.9 (13.9–15.9) | 7.9 (5.1–10.7) | 18.9 (16.8–21.1) | 18.2 (16.5–19.8) | 8.5 (7.2–9.8)
Iowa | 11.8 (11.0–12.6) | 5.4 (3.5–7.3) | 16.5 (14.8–18.2) | 13.9 (12.4–15.3) | 6.2 (5.1–7.2)
Kansas | 12.2 (11.3–13.1) | 5.9 (3.6–8.2) | 14.8 (13.0–16.6) | 15.8 (14.2–17.3) | 7.2 (6.0–8.3)
Kentucky | 16.6 (15.0–18.1) | 7.9 (3.5–12.3) | 20.5 (17.3–23.7) | 20.4 (17.7–23.0) | 10.1 (7.8–12.3)
Louisiana | 12.6 (11.3–14.0) | 6.1 (2.7–9.4) | 15.9 (13.1–18.6) | 15.1 (12.9–17.4) | 7.5 (5.8–9.2)
Maine | 13.1 (12.0–14.2) | 8.7 (4.2–13.2) | 18.4 (15.9–20.9) | 14.7 (13.0–16.4) | 7.1 (6.0–8.3)
Maryland | 7.0 (6.4–7.7) | —^b^ | 8.9 (7.6–10.2) | 8.3 (7.3–9.3) | 4.9 (4.1–5.7)
Massachusetts | 7.7 (6.8–8.6) | 4.3 (2.2–6.4) | 9.9 (7.8–12.0) | 8.8 (7.4–10.2) | 4.9 (3.4–6.4)
Michigan | 13.2 (12.1–14.4) | 7.1 (4.3–9.9) | 16.5 (14.1–18.8) | 17.1 (14.9–19.2) | 6.7 (5.4–8.0)
Minnesota | 9.9 (9.3–10.5) | 3.8 (2.4–5.2) | 13.1 (11.9–14.3) | 11.4 (10.4–12.4) | 6.2 (5.3–7.1)
Mississippi | 14.0 (12.8–15.2) | 6.3 (3.0–9.5) | 17.9 (15.4–20.4) | 17.2 (15.2–19.2) | 6.9 (5.4–8.3)
Missouri | 13.8 (12.8–14.8) | 7.0 (4.5–9.5) | 17.5 (15.3–19.6) | 16.2 (14.4–17.9) | 8.9 (7.5–10.4)
Montana | 12.0 (11.0–13.1) | 5.8 (3.4–8.1) | 17.3 (14.8–19.7) | 12.4 (10.7–14.2) | 7.9 (6.4–9.4)
Nebraska | 10.1 (9.4–10.9) | 3.8 (2.3–5.4) | 12.5 (11.0–14.0) | 13.7 (12.3–15.1) | 5.3 (4.5–6.2)
Nevada | 9.2 (7.7–10.7) | —^b^ | 10.2 (7.4–13.0) | 11.3 (8.5–14.1) | 8.0 (5.5–10.5)
New Hampshire | 10.0 (8.9–11.1) | —^b^ | 13.5 (10.7–16.2) | 11.2 (9.6–12.8) | 7.2 (5.5–8.9)
New Jersey | 7.1 (6.5–7.8) | —^b^ | 8.3 (6.9–9.7) | 9.3 (8.1–10.5) | 5.2 (4.2–6.2)
New Mexico | 9.9 (8.7–11.2) | 4.3 (1.9–6.8) | 13.1 (10.2–15.9) | 11.8 (9.5–14.0) | 6.3 (4.8–7.8)
New York | 8.0 (7.3–8.6) | 3.2 (1.7–4.7) | 9.3 (8.0–10.6) | 10.7 (9.5–11.9) | 4.6 (3.7–5.4)
North Carolina | 12.6 (11.5–13.7) | 4.8 (2.5–7.2) | 15.2 (13.0–17.5) | 15.2 (13.2–17.2) | 8.9 (7.1–10.6)
North Dakota | 12.7 (11.2–14.2) | 11.7 (6.6–16.9) | 15.8 (12.6–18.9) | 13.4 (11.1–15.7) | 7.2 (5.7–8.8)
Ohio | 14.9 (14.0–15.7) | 7.0 (4.9–9.1) | 20.0 (18.0–21.9) | 17.5 (16.1–19.0) | 8.4 (7.2–9.5)
Oklahoma | 14.0 (12.8–15.3) | 5.8 (3.0–8.5) | 16.0 (13.5–18.5) | 18.6 (16.3–21.0) | 9.4 (7.6–11.1)
Oregon | 10.0 (9.0–11.0) | 6.6 (3.7–9.6) | 11.4 (9.6–13.2) | 12.0 (10.3–13.8) | 7.0 (5.2–8.7)
Pennsylvania | 11.9 (10.8–13.1) | 4.3 (2.0–6.6) | 16.4 (13.9–19.0) | 13.5 (11.6–15.3) | 7.7 (5.6–9.7)
Rhode Island | 10.1 (8.7–11.4) | —^b^ | 12.5 (9.7–15.4) | 13.0 (10.8–15.2) | 6.0 (4.4–7.6)
South Carolina | 13.3 (11.8–14.7) | 5.7 (2.4–9.1) | 16.2 (13.0–19.3) | 18.3 (15.6–21.0) | 6.4 (4.7–8.1)
South Dakota | 12.5 (10.6–14.5) | —^b^ | 17.6 (12.9–22.3) | 13.1 (10.2–16.0) | 7.1 (5.1–9.1)
Tennessee | 15.1 (13.6–16.6) | —^b^ | 16.4 (13.7–19.0) | 19.4 (16.5–22.2) | 11.2 (8.7–13.7)
Texas | 8.3 (7.3–9.2) | 4.0 (2.1–6.0) | 9.0 (7.1–10.8) | 10.6 (8.8–12.5) | 5.9 (4.3–7.5)
Utah | 5.4 (4.8–5.9) | 2.5 (1.3–3.7) | 6.2 (5.2–7.3) | 7.4 (6.2–8.6) | 2.6 (1.8–3.3)
Vermont | 9.6 (8.5–10.6) | —^b^ | 13.3 (10.9–15.7) | 11.9 (10.1–13.7) | 5.9 (4.3–7.5)
Virginia | 9.6 (8.8–10.5) | 3.5 (1.8–5.1) | 11.0 (9.3–12.6) | 12.3 (10.8–13.8) | 7.2 (5.7–8.7)
Washington | 7.7 (7.1–8.4) | 2.6 (1.4–3.8) | 8.9 (7.7–10.1) | 9.7 (8.5–10.9) | 5.7 (4.6–6.7)
West Virginia | 18.2 (16.9–19.5) | 6.5 (2.9–10.0) | 26.3 (23.4–29.3) | 21.8 (19.6–23.9) | 9.7 (8.1–11.2)
Wisconsin | 10.8 (9.5–12.1) | —^b^ | 12.9 (10.1–15.7) | 14.3 (12.0–16.7) | 6.7 (5.1–8.3)
Wyoming | 13.6 (12.1–15.2) | 11.4 (6.0–16.8) | 17.8 (14.6–21.0) | 14.1 (11.8–16.5) | 8.2 (6.6–9.9)
Region
Northeast | 9.0 (8.6–9.4) | 3.4 (2.6–4.3) | 11.4 (10.5–12.2) | 10.9 (10.3–11.6) | 5.7 (5.1–6.3)
Midwest | 12.3 (12.0–12.7) | 6.3 (5.4–7.2) | 15.2 (14.5–15.9) | 15.2 (14.5–15.9) | 7.5 (6.9–8.1)
South | 10.9 (10.6–11.3) | 4.5 (3.7–5.2) | 13.0 (12.3–13.7) | 13.8 (13.1–14.4) | 7.3 (6.8–7.8)
West | 7.4 (6.9–7.9) | 3.6 (2.5–1.7) | 8.5 (7.5–9.4) | 8.9 (7.9–9.9) | 5.3 (4.6–6.1)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes:CI = confidence interval.

a Daily use of cigarettes was defined as having smoked at least 100 cigarettes in one’s lifetime and smoked every day at the time of the survey.

b Estimate is not presented because of a relative standard error ≥30%. Relative standard error is equal to the standard error of a survey estimate divided by the survey estimate and then multiplied by 100.

Table 2.28 Prevalence of nondaily use of cigarettes^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 5.2 (4.4–6.1) | —^b^ | 7.3 (5.4–9.2) | 5.4 (4.1–6.8) | 2.2 (1.4–3.0)
Alaska | 4.5 (3.5–5.5) | —^b^ | 6.3 (4.2–8.4) | 5.0 (3.4–6.6) | 1.1 (0.5–1.6)
Arizona | 4.1 (3.5–4.7) | 4.0 (2.2–5.8) | 5.7 (4.4–6.9) | 3.8 (2.9–4.6) | 2.4 (1.7–3.1)
Arkansas | 5.4 (4.5–6.4) | —^b^ | 6.3 (4.4–8.3) | 6.4 (4.8–8.1) | 3.0 (2.0–3.9)
California | 3.0 (2.3–3.6) | —^b^ | 4.0 (2.8–5.2) | 3.0 (1.7–4.3) | —^b^
Colorado | 3.9 (3.5–4.4) | 3.5 (2.1–4.8) | 5.1 (4.1–6.0) | 3.7 (3.0–4.5) | 2.4 (1.7–3.2)
Connecticut | 3.6 (3.0–4.3) | —^b^ | 5.2 (3.9–6.5) | 3.8 (2.7–5.0) | 1.9 (1.1–2.7)
Delaware | 4.5 (3.5–5.5) | —^b^ | 5.8 (3.7–7.9) | 4.4 (2.8–6.0) | 3.5 (1.9–5.1)
District of Columbia | 5.2 (4.1–6.4) | —^b^ | 5.1 (3.3–6.9) | 7.0 (5.2–8.8) | 3.4 (2.1–4.8)
Florida | 5.3 (4.1–6.4) | 3.7 (1.6–5.7) | 7.4 (4.6–10.3) | 6.7 (4.5–8.9) | 1.8 (1.1–2.4)
Georgia | 5.0 (4.2–5.8) | 3.6 (1.6–5.7) | 6.4 (4.7–8.1) | 5.1 (4.0–6.2) | 3.3 (2.4–4.2)
Hawai‘i | 3.6 (3.0–4.2) | 6.7 (3.7–9.7) | 4.7 (3.5–5.8) | 2.9 (2.0–3.8) | 1.8 (1.1–2.5)
Idaho | 4.0 (3.2–4.7) | 5.0 (2.6–7.3) | 5.7 (4.1–7.2) | 3.5 (2.2–4.8) | 1.5 (0.8–2.2)
Illinois | 3.2 (2.5–4.0) | —^b^ | 4.6 (3.1–6.0) | 2.8 (1.4–4.1) | 1.8 (0.8–2.7)
Indiana | 4.5 (3.9–5.0) | 3.5 (1.7–5.3) | 5.4 (4.2–6.7) | 5.1 (4.1–6.0) | 2.7 (1.9–3.4)
Iowa | 4.0 (3.5–4.5) | 4.6 (2.9–6.4) | 5.7 (4.6–6.9) | 3.8 (3.0–4.6) | 1.5 (1.1–2.0)
Kansas | 4.4 (3.8–5.0) | 4.6 (2.7–6.5) | 5.3 (4.2–6.4) | 4.9 (3.9–5.9) | 2.2 (1.6–2.8)
Kentucky | 4.8 (3.9–5.7) | —^b^ | 6.2 (4.4–8.0) | 4.9 (3.4–6.3) | 2.9 (1.6–4.3)
Louisiana | 5.7 (4.7–6.6) | —^b^ | 6.1 (4.4–7.8) | 7.0 (5.3–8.6) | 2.8 (1.8–3.9)
Maine | 3.4 (2.8–4.1) | —^b^ | 6.0 (4.2–7.8) | 2.6 (1.9–3.3) | 1.7 (1.3–2.2)
Maryland | 3.8 (3.3–4.4) | 3.1 (1.6–4.6) | 5.1 (4.0–6.3) | 3.9 (3.1–1.7) | 2.2 (1.5–2.9)
Massachusetts | 3.4 (2.7–4.0) | —^b^ | 3.6 (2.5–4.6) | 4.0 (2.8–5.2) | 2.6 (1.4–3.7)
Michigan | 5.2 (4.4–5.9) | 3.7 (1.8–5.6) | 7.0 (5.3–8.7) | 5.3 (4.2–6.5) | 3.2 (2.3–4.1)
Minnesota | 3.9 (3.5–4.3) | 4.0 (2.7–5.3) | 5.1 (4.4–5.9) | 3.8 (3.2–1.4) | 2.3 (1.7–2.8)
Mississippi | 6.1 (5.2–7.0) | —^b^ | 8.0 (6.1–9.8) | 6.2 (4.8–7.5) | 3.8 (2.8–4.9)
Missouri | 4.0 (3.4–4.5) | 2.8 (1.4–4.3) | 5.3 (4.2–6.5) | 4.3 (3.3–5.3) | 2.1 (1.4–2.9)
Montana | 4.4 (3.7–5.1) | 6.5 (3.7–9.4) | 6.1 (4.5–7.7) | 3.5 (2.-4.4) | 2.3 (1.5–3.1)
Nebraska | 3.8 (3.3–4.3) | 4.1 (2.5–5.8) | 5.2 (4.1–6.3) | 3.5 (2.7–4.3) | 1.9 (1.4–2.4)
Nevada | 5.1 (3.9–6.2) | —^b^ | 4.7 (2.7–6.6) | 6.0 (3.7–8.3) | 5.4 (2.9–7.9)
New Hampshire | 3.9 (3.1–4.6) | —^b^ | 5.4 (3.7–7.1) | 3.6 (2.6–4.6) | 1.4 (0.9–2.0)
New Jersey | 3.7 (3.2–4.2) | 3.5 (2.0–5.1) | 5.5 (4.4–6.6) | 3.4 (2.7–4.1) | 1.5 (0.9–2.1)
New Mexico | 6.1 (5.1–7.1) | 5.4 (2.3–8.5) | 8.9 (6.5–11.3) | 4.8 (3.5–6.1) | 4.4 (2.8–6.0)
New York | 4.0 (3.5–4.5) | 2.3 (1.1–3.4) | 5.2 (4.1–6.3) | 4.6 (3.8–5.4) | 2.3 (1.7–2.8)
North Carolina | 4.0 (3.3–4.6) | 3.6 (1.8–5.5) | 5.0 (3.7–6.4) | 4.6 (3.4–5.8) | 1.6 (1.0–2.2)
North Dakota | 4.7 (3.7–5.7) | —^b^ | 6.0 (3.9–8.1) | 4.4 (2.9–5.8) | 2.6 (1.6–3.5)
Ohio | 4.4 (3.9–4.9) | 3.5 (2.1–4.9) | 5.2 (4.2–6.3) | 5.1 (4.3–5.9) | 2.8 (2.1–3.6)
Oklahoma | 5.1 (4.1–6.0) | 5.3 (2.3–8.3) | 7.2 (5.1–9.2) | 3.9 (2.8–5.1) | 3.2 (2.1–4.3)
Oregon | 3.3 (2.8–3.9) | 4.5 (2.2–6.8) | 3.4 (2.4–4.4) | 3.9 (2.9–4.9) | 1.9 (1.1–2.7)
Pennsylvania | 3.8 (3.2–4.5) | —^b^ | 4.8 (3.5–6.1) | 3.9 (2.7–5.2) | 2.5 (1.6–3.4)
Rhode Island | 3.4 (2.7–4.1) | —^b^ | 4.3 (2.7–5.8) | 3.2 (2.1–4.2) | 2.4 (1.4–3.4)
South Carolina | 4.9 (4.0–5.8) | 6.5 (3.1–9.8) | 5.3 (3.5–7.0) | 4.8 (3.4–6.3) | 3.6 (2.2–5.0)
South Dakota | 5.2 (3.8–6.6) | —^b^ | 8.5 (5.0–11.9) | 4.4 (2.5–6.4) | 2.4 (1.3–3.5)
Tennessee | 4.4 (3.6–5.2) | 6.4 (3.1–9.7) | 4.7 (3.2–6.2) | 4.4 (3.2–5.7) | 2.8 (1.6–4.1)
Texas | 4.9 (4.1–5.8) | 4.5 (2.4–6.7) | 6.3 (4.6–7.9) | 5.1 (3.7–6.4) | 2.4 (1.3–3.5)
Utah | 2.8 (2.3–3.3) | 2.4 (1.3–3.4) | 3.8 (2.8–4.8) | 2.8 (1.9–3.6) | 0.8 (0.4–1.3)
Vermont | 3.7 (2.8–4.6) | —^b^ | 5.4 (3.6–7.3) | 2.5 (1.7–3.2) | 1.2 (0.7–1.6)
Virginia | 4.0 (3.4–4.6) | 4.9 (2.8–7.0) | 5.6 (4.3–6.8) | 3.1 (2.4–3.8) | 2.3 (1.5–3.1)
Washington | 3.7 (3.3–4.2) | 3.5 (2.0–5.0) | 4.9 (3.9–5.8) | 3.6 (2.9–4.3) | 2.3 (1.5–3.1)
West Virginia | 4.3 (3.7–5.0) | —^b^ | 4.9 (3.6–6.2) | 5.7 (4.6–6.8) | 3.0 (2.2–3.9)
Wisconsin | 4.7 (3.8–5.6) | —^b^ | 6.8 (4.6–9.1) | 4.0 (2.8–5.1) | 3.3 (1.8–4.7)
Wyoming | 4.8 (3.8–5.8) | —^b^ | 6.8 (4.8–8.9) | 4.2 (2.7–5.7) | 2.3 (1.4–3.2)
Region
Northeast | 3.8 (3.5–4.0) | 3.1 (2.2–3.9) | 5.0 (4.4–5.5) | 4.0 (3.6–4.4) | 2.2 (1.8–2.5)
Midwest | 4.2 (4.0–4.5) | 3.6 (3.0–4.3) | 5.6 (5.1–6.1) | 4.3 (3.9–4.7) | 2.5 (2.2–2.8)
South | 4.8 (4.5–5.1) | 4.5 (3.7–5.2) | 6.2 (5.5–6.9) | 5.2 (4.7–5.7) | 2.4 (2.1–2.7)
West | 3.5 (3.2–3.8) | 3.5 (2.5–4.6) | 4.6 (3.9–5.2) | 3.4 (2.8–4.1) | 1.7 (1.4–2.1)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes:CI = confidence interval.

a Daily use of cigarettes was defined as having smoked at least 100 cigarettes in one’s lifetime and smoked every day at the time of the survey.

b Estimate is not presented because of a relative standard error ≥30%. Relative standard error is equal to the standard error of a survey estimate divided by the survey estimate and then multiplied by 100.

Table 2.29 Prevalence of stopping cigarette smoking for 1 day or longer during the past 12 months^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region % (95% CI) | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 68.5 (64.8–72.2) | 97.4 (94.2–100.0) | 72.5 (66.6–78.4) | 60.6 (54.3–66.9) | 52.4 (43.8–61.1)
Alaska | 64.6 (59.3–69.9) | 78.1 (62.4–93.9) | 68.3 (60.5–76.2) | 62.6 (54.4–70.7) | 35.0 (22.3–47.6)
Arizona | 62.0 (58.6–65.5) | 82.5 (71.5–93.6) | 67.6 (62.0–73.2) | 52.3 (46.8–57.8) | 54.2 (46.5–61.9)
Arkansas | 56.9 (52.7–61.1) | 71.2 (53.8–88.6) | 56.9 (50.0–63.9) | 56.8 (50.5–63.1) | 47.8 (40.2–55.5)
California | 69.4 (64.0–74.9) | 76.4 (60.1–92.6) | 73.2 (65.4–81.0) | 65.3 (55.1–75.5) | 59.9 (45.9–73.9)
Colorado | 67.3 (64.5–70.1) | 84.1 (76.5–91.7) | 70.5 (66.4–74.6) | 58.4 (53.6–63.3) | 59.9 (52.6–67.2)
Connecticut | 69.3 (65.5–73.1) | 85.0 (71.3–98.6) | 71.9 (65.7–78.2) | 63.8 (57.7–70.0) | 66.4 (57.0–75.8)
Delaware | 65.0 (59.7–70.2) | 87.2 (73.0–100.0) | 63.9 (55.4–72.4) | 61.8 (54.1–69.5) | 64.2 (50.0–78.5)
District of Columbia | 71.0 (65.2–76.8) | 70.3 (35.7–100.0) | 71.6 (62.8–80.5) | 70.4 (62.6–78.2) | 70.2 (58.4–82.0)
Florida | 62.5 (57.8–67.2) | 86.1 (77.0–95.1) | 65.5 (57.0–73.9) | 55.7 (48.1–63.4) | 59.8 (51.4–68.2)
Georgia | 65.6 (61.6–69.5) | 76.4 (63.4–89.4) | 70.5 (63.9–77.1) | 59.9 (53.5–66.2) | 56.5 (48.8–64.1)
Hawai‘i | 63.0 (58.8–67.2) | 77.6 (66.5–88.8) | 66.7 (60.1–73.3) | 58.3 (51.0–65.5) | 49.3 (39.0–59.7)
Idaho | 61.8 (57.6–66.1) | 71.2 (58.1–84.3) | 69.2 (63.0–75.5) | 49.7 (42.2–57.3) | 58.4 (48.7–68.2)
Illinois | 60.6 (55.3–65.8) | 77.6 (61.2–94.1) | 67.8 (60.3–75.2) | 52.0 (42.7–61.4) | 53.3 (40.3–66.3)
Indiana | 59.4 (56.5–62.2) | 78.7 (68.4–89.0) | 63.2 (58.4–68.0) | 53.9 (49.7–58.0) | 49.5 (43.0–56.1)
Iowa | 59.9 (57.1–62.7) | 74.4 (64.8–84.0) | 62.9 (58.5–67.3) | 52.7 (48.2–57.2) | 56.1 (49.0–63.3)
Kansas | 59.6 (56.6–62.5) | 71.2 (59.5–82.9) | 61.5 (56.7–66.3) | 56.1 (51.6–60.6) | 52.3 (45.5–59.1)
Kentucky | 55.5 (51.3–59.6) | 63.7 (45.0–82.5) | 57.5 (50.8–64.3) | 52.5 (46.2–58.8) | 52.1 (42.4–61.7)
Louisiana | 64.2 (60.1–68.3) | 78.4 (65.3–91.5) | 65.1 (58.3–71.8) | 60.0 (53.7–66.2) | 60.5 (51.5–69.5)
Maine | 57.2 (53.5–60.8) | 69.9 (52.7–87.2) | 57.6 (51.4–63.7) | 56.3 (51.0–61.5) | 50.7 (43.9–57.5)
Maryland | 64.0 (60.7–67.2) | 75.5 (62.1–88.9) | 66.5 (61.2–71.8) | 63.3 (58.4–68.2) | 50.8 (43.6–58.0)
Massachusetts | 65.8 (61.5–70.1) | 69.2 (52.7–85.6) | 67.8 (60.6–75.0) | 61.6 (55.0–68.2) | 68.8 (59.4–78.2)
Michigan | 63.1 (59.5–66.6) | 72.4 (60.9–83.9) | 64.5 (58.6–70.5) | 59.2 (53.6–64.9) | 63.5 (56.2–70.8)
Minnesota | 59.8 (57.5–62.2) | 77.6 (68.1–87.1) | 63.7 (60.1–67.2) | 55.6 (51.9–59.2) | 45.6 (39.5–51.8)
Mississippi | 66.1 (62.6–69.6) | 76.9 (62.5–91.4) | 70.2 (64.6–75.8) | 61.7 (56.4–67.0) | 55.8 (48.1–63.4)
Missouri | 60.6 (57.6–63.6) | 78.9 (69.0–88.8) | 63.6 (58.6–68.5) | 56.4 (51.6–61.2) | 51.2 (44.1–58.3)
Montana | 60.4 (56.8–64.1) | 80.4 (71.4–89.4) | 66.3 (60.5–72.1) | 54.0 (47.8–60.1) | 38.2 (30.4–46.0)
Nebraska | 61.8 (58.8–64.7) | 77.1 (68.2–86.1) | 68.4 (63.9–73.0) | 52.8 (47.9–57.6) | 46.5 (40.0–52.9)
Nevada | 62.6 (56.8–68.5) | 68.7 (48.0–89.4) | 65.0 (55.6–74.5) | 63.6 (53.6–73.6) | 53.0 (40.1–65.9)
New Hampshire | 60.2 (55.5–64.9) | 85.4 (65.7–100.0) | 60.9 (52.9–68.9) | 57.4 (51.0–63.9) | 51.2 (40.5–61.9)
New Jersey | 68.5 (65.3–71.8) | 89.9 (81.4–98.4) | 71.3 (65.9–76.7) | 64.8 (59.8–69.8) | 60.7 (52.9–68.6)
New Mexico | 65.4 (60.9–69.9) | 74.4 (60.0–88.8) | 71.2 (64.2–78.1) | 54.1 (46.3–62.0) | 64.6 (55.6–73.6)
New York | 66.5 (63.7–69.4) | 84.7 (76.2–93.3) | 70.5 (65.6–75.3) | 60.0 (55.6–64.5) | 61.8 (55.2–68.4)
North Carolina | 60.1 (56.3–63.8) | 75.5 (63.2–87.8) | 64.1 (58.1–70.1) | 56.1 (50.2–62.1) | 48.5 (39.7–57.4)
North Dakota | 58.7 (53.6–63.8) | 53.6 (35.7–71.5) | 66.4 (58.6–74.1) | 50.7 (42.9–58.4) | 50.7 (41.8–59.6)
Ohio | 58.9 (56.4–61.4) | 71.1 (61.0–81.3) | 60.5 (56.3–64.7) | 55.3 (51.5–59.1) | 56.6 (50.8–62.3)
Oklahoma | 60.7 (56.9–64.5) | 71.6 (57.7–85.6) | 68.5 (62.4–74.7) | 53.0 (46.9–59.1) | 50.2 (42.3–58.0)
Oregon | 59.5 (55.6–63.4) | 68.4 (54.2–82.6) | 67.2 (61.3–73.0) | 51.8 (45.5–58.1) | 48.8 (38.3–59.4)
Pennsylvania | 60.9 (56.9–64.8) | 87.1 (77.8–96.3) | 62.8 (56.6–69.1) | 54.8 (48.4–61.2) | 57.4 (47.4–67.5)
Rhode Island | 65.5 (60.6–70.5) | 71.7 (44.4–98.9) | 69.1 (61.1–77.1) | 62.8 (55.7–70.0) | 58.6 (48.4–68.8)
South Carolina | 61.8 (57.3–66.4) | 82.1 (69.2–95.0) | 62.5 (54.6–70.5) | 55.5 (48.7–62.3) | 63.8 (54.8–72.9)
South Dakota | 59.8 (53.6–66.1) | 84.3 (68.9–99.6) | 65.4 (55.6–75.2) | 46.3 (36.4–56.2) | 48.0 (36.2–59.8)
Tennessee | 57.6 (53.1–62.2) | 64.8 (41.7–87.8) | 62.8 (56.0–69.6) | 54.2 (47.2–61.1) | 48.3 (38.3–58.4)
Texas | 65.8 (61.6–70.0) | 77.1 (65.4–88.7) | 69.8 (63.2–76.3) | 59.1 (52.1–66.1) | 57.5 (44.5–70.4)
Utah | 67.7 (63.9–71.6) | 80.0 (69.9–90.2) | 71.8 (66.4–77.2) | 57.2 (50.4–63.9) | 64.1 (51.2–77.1)
Vermont | 62.4 (57.7–67.1) | 83.9 (69.8–98.0) | 66.1 (59.0–73.1) | 54.0 (47.4–60.7) | 46.2 (35.4–57.1)
Virginia | 65.2 (62.0–68.3) | 82.9 (73.4–92.3) | 67.5 (62.4–72.7) | 57.9 (52.7–63.2) | 62.7 (56.0–69.5)
Washington | 64.2 (61.2–67.1) | 76.3 (65.2–87.3) | 69.6 (65.2–74.0) | 58.8 (53.9–63.7) | 52.3 (44.8–59.8)
West Virginia | 57.0 (53.8–60.2) | 81.1 (68.2–94.0) | 55.5 (50.0–60.9) | 55.5 (50.9–60.2) | 53.7 (46.9–60.5)
Wisconsin | 60.8 (56.1–65.6) | 65.2 (45.1–85.3) | 66.3 (58.4–74.1) | 56.7 (49.6–63.8) | 52.7 (42.7–62.8)
Wyoming | 59.7 (55.1–64.4) | 74.0 (59.1–89.0) | 60.9 (53.6–68.3) | 54.2 (46.7–61.7) | 52.9 (44.1–61.6)
Region
Northeast | 64.8 (63.1–66.4) | 82.9 (78.1–87.7) | 67.4 (64.7–70.1) | 59.5 (57.0–62.1) | 60.4 (56.3–64.4)
Midwest | 60.4 (59.2–61.7) | 74.1 (69.8–78.4) | 63.9 (62.0–65.9) | 55.3 (53.3–57.4) | 54.3 (51.2–57.3)
South | 62.9 (61.5–64.2) | 78.2 (73.9–82.4) | 66.3 (64.0–68.5) | 57.4 (55.2–59.6) | 55.8 (52.5–59.2)
West | 66.0 (63.6–68.3) | 76.8 (69.2–84.4) | 70.5 (67.1–73.9) | 60.1 (55.6–64.7) | 56.1 (50.6–61.6)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes: CI = confidence interval.

a Includes people who (a) currently smoked cigarettes and stopped smoking for 1 day or longer during the past year because they were trying to quit smoking and (b) quit smoking during the past year.

Table 2.30 Prevalence of quitting cigarette smoking for at least 6 months^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region % (95% CI) | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 5.1 (3.3–6.8) | —^b^ | 5.2 (2.9–7.5) | —^b^ | —^b^
Alaska | 3.4 (1.5–5.3) | —^b^ | —^b^ | —^b^ | —^b^
Arizona | 6.0 (4.3–7.7) | —^b^ | 5.6 (2.9–8.3) | 5.6 (2.9–8.3) | —^b^
Arkansas | 4.0 (2.5–5.5) | —c | 5.9 (2.8–8.9) | —^b^ | —^b^
California | 8.0 (5.2–10.8) | —^b^ | 9.5 (5.1–13.9) | —^b^ | —^b^
Colorado | 8.4 (6.7–10.1) | —^b^ | 10.0 (7.2–12.8) | 6.7 (4.4–9.0) | —^b^
Connecticut | 5.3 (3.4–7.1) | —^b^ | 4.7 (2.2–7.2) | 6.3 (2.7–9.9) | —^b^
Delaware | 3.6 (1.5–5.7) | —^b^ | —^b^ | —^b^ | —^b^
District of Columbia | 7.0 (3.9–10.1) | —^b^ | 11.0 (5.4–16.6) | —^b^ | —^b^
Florida | 5.1 (3.3–6.8) | —^b^ | 6.7 (3.2–10.1) | 3.4 (1.5–5.3) | —^b^
Georgia | 6.3 (4.3–8.3) | —^b^ | 8.7 (4.9–12.5) | 2.5 (1.3–3.7) | —^b^
Hawai‘i | 5.4 (3.6–7.2) | —^b^ | 4.7 (2.6–6.8) | 5.5 (2.3–8.7) | —^b^
Idaho | 6.0 (4.0–8.0) | —^b^ | 7.7 (3.9–11.4) | —^b^ | —^b^
Illinois | 7.8 (5.1–10.4) | —^b^ | 9.0 (4.1–13.9) | 6.0 (2.6–9.4) | —^b^
Indiana | 4.2 (3.0–5.4) | —^b^ | 4.5 (2.5–6.6) | 3.6 (2.1–5.2) | —^b^
Iowa | 4.6 (3.4–5.8) | —^b^ | 4.4 (2.5–6.3) | 5.0 (3.1–7.0) | —^b^
Kansas | 6.5 (5.0–8.1) | —^b^ | 9.2 (6.3–12.1) | 3.6 (2.0–5.2) | —^b^
Kentucky | 5.7 (4.0–7.5) | —^b^ | 6.5 (3.7–9.4) | 3.5 (1.7–5.2) | —^b^
Louisiana | 6.1 (3.8–8.3) | —^b^ | 8.1 (3.8–12.3) | —^b^ | —^b^
Maine | 7.1 (4.9–9.4) | —^b^ | 8.8 (4.8–12.7) | 3.6 (1.7–5.5) | 6.3 (3.1–9.5)
Maryland | 5.8 (4.3–7.3) | —^b^ | 5.7 (3.6–7.9) | 4.9 (2.6–7.2) | —^b^
Massachusetts | 5.9 (4.2–7.5) | —^b^ | 8.8 (5.4–12.2) | —^b^ | —^b^
Michigan | 5.0 (3.6–6.4) | 14.6 (6.2–23.0) | 4.8 (2.6–7.0) | 2.7 (1.3–4.2) | 5.9 (2.4–9.3)
Minnesota | 6.4 (5.1–7.7) | —^b^ | 7.3 (5.4–9.2) | 4.5 (3.0–6.0) | —^b^
Mississippi | 3.3 (2.1–4.5) | —^b^ | 4.9 (2.5–7.2) | —^b^ | —^b^
Missouri | 6.1 (4.6–7.6) | —^b^ | 6.5 (4.1–8.9) | 5.8 (3.4–8.3) | —^b^
Montana | 6.7 (4.5–8.9) | —^b^ | 8.7 (4.5–13.0) | 4.8 (2.4–7.3) | —^b^
Nebraska | 6.3 (4.7–7.9) | —^b^ | 7.4 (4.7–10.2) | 3.7 (1.7–5.6) | 3.8 (2.1–5.4)
Nevada | 9.8 (5.0–14.7) | —^b^ | —^b^ | —^b^ | —^b^
New Hampshire | 5.2 (2.6–7.8) | —^c^ | —^b^ | —^b^ | —^b^
New Jersey | 7.1 (5.3–8.9) | —^b^ | 9.4 (6.1–12.7) | 4.2 (2.5–5.9) | —^b^
New Mexico | 6.6 (4.3–8.9) | —^b^ | 6.8 (3.5–10.1) | 3.0 (1.3–4.7) | —^b^
New York | 6.7 (5.2–8.2) | —^b^ | 7.9 (5.2–10.6) | 5.2 (3.3–7.2) | 5.1 (2.7–7.4)
North Carolina | 6.8 (4.7–8.9) | —^b^ | 8.5 (4.5–12.5) | —^b^ | —^b^
North Dakota | 5.7 (3.2–8.2) | —^b^ | —^b^ | —^b^ | —^b^
Ohio | 4.0 (3.0–5.0) | —^b^ | 4.5 (2.9–6.0) | 3.1 (2.0–4.3) | —^b^
Oklahoma | 4.3 (2.7–5.8) | —^b^ | 4.3 (1.9–6.6) | —^b^ | —^b^
Oregon | 8.1 (5.7–10.4) | —^b^ | 10.9 (6.8–15.0) | —^b^ | —^b^
Pennsylvania | 6.1 (4.3–8.0) | —^b^ | 8.0 (4.7–11.4) | 4.2 (1.9–6.6) | —^b^
Rhode Island | 8.5 (5.2–11.8) | —^b^ | 11.1 (5.6–16.7) | —^b^ | —^b^
South Carolina | 5.7 (3.4–8.0) | —^b^ | —^b^ | —^b^ | —^b^
South Dakota | 5.3 (2.1–8.4) | —^b^ | —^b^ | —^b^ | —^b^
Tennessee | 5.0 (2.5–7.4) | —^b^ | 8.1 (4.1–12.2) | —^b^ | —^b^
Texas | 7.2 (4.8–9.6) | —^b^ | 9.7 (5.2–14.2) | —^b^ | —^b^
Utah | 10.2 (7.5–12.9) | —^b^ | 10.9 (7.0–14.9) | 7.3 (3.8–10.9) | —^b^
Vermont | 6.8 (3.5–10.0) | —^b^ | —^b^ | —^b^ | —^b^
Virginia | 7.3 (5.4–9.2) | —^b^ | 8.7 (5.4–11.9) | 2.8 (1.2–4.5) | 8.0 (3.6–12.4)
Washington | 8.1 (6.4–9.9) | —^b^ | 10.7 (7.5–13.9) | 4.4 (2.7–6.1) | 8.3 (4.2–12.3)
West Virginia | 5.7 (4.0–7.4) | —^b^ | 7.0 (4.3–9.8) | —^b^ | —^b^
Wisconsin | 8.0 (5.2–10.7) | —^c^ | 11.0 (5.6–16.4) | 8.4 (4.4–12.4) | —^b^
Wyoming | 7.1 (4.5–9.7) | —^b^ | —^b^ | 8.1 (3.6–12.5) | —^b^
Region
Northeast | 6.4 (5.6–7.2) | 7.6 (4.4–10.8) | 8.1 (6.7–9.6) | 4.6 (3.6–5.6) | 5.4 (3.6–7.2)
Midwest | 5.7 (5.1–6.2) | 8.5 (6.0–11.1) | 6.4 (5.4–7.4) | 4.4 (3.7–5.2) | 4.7 (3.3–6.1)
South | 5.9 (5.2–6.6) | 10.4 (7.5–13.3) | 7.7 (6.4–9.0) | 3.2 (2.5–3.9) | 4.3 (3.1–5.5)
West | 7.7 (6.5–9.0) | 9.9 (5.4–14.3) | 9.0 (7.0–10.9) | 6.4 (4.1–8.8) | 5.0 (3.2–6.8)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes: CI = confidence interval.

a Having quit smoking cigarettes for at least 6 months during the past year, among people who currently smoked cigarettes and among those who quit smoking during the past year.

b Estimate is not presented because of a relative standard error >30%. Relative standard error is equal to the standard error of a survey estimate divided by the survey estimate and multiplied by 100.

c Data were not available for this age group in this state.

Table 2.31 Prevalence of the use of electronic vapor products^a^ among high school students, by location; national Youth Risk Behavior Survey (YRBS) 2019, United States

Location | Ever use:^b^ % (95% CI) | Past-30-day use:^c^ % (95% CI) | >20-days use:^d^ % (95% CI) | Daily use:^e^ % (95% CI)
Alabama | 54.4 (47.7–61.0) | 19.4 (15.8–23.6) | 7.5 (5.5–10.1) | 5.5 (4.1–7.4)
Alaska | 45.8 (42.8–48.9) | 26.1 (22.6–29.9) | 6.8 (4.6–9.9) | 4.5 (2.7–7.6)
Arizona | 48.4 (43.8–53.0) | 17.9 (14.0–22.7) | 7.8 (4.6–12.7) | 5.7 (3.4–9.3)
Arkansas | 51.5 (46.8–56.2) | 24.3 (20.5–28.6) | 10.1 (7.4–13.8) | 8.5 (6.0–11.8)
California | 42.3 (36.4–48.4) | 18.2 (15.3–21.4) | 3.6 (2.4–5.4) | 2.4 (1.4–4.1)
Colorado | 50.3 (46.2–54.4) | 28.9 (24.8–33.4) | 9.9 (7.2–13.5) | 7.1 (4.9–10.1)
Connecticut | 44.8 (40.1–49.7) | 27.0 (22.8–31.7) | 8.5 (6.1–11.7) | 6.1 (4.1–8.9)
Delaware | —^f^ | —^f^ | —^f^ | —^f^
District of Columbia | —^f^ | —^f^ | —^f^ | —^f^
Florida | —^f^ | —^f^ | —^f^ | —^f^
Georgia | 42.3 (38.5–46.2) | 17.0 (13.9–20.6) | 5.4 (3.5–8.0) | 3.9 (2.6–5.9)
Hawai‘i | 48.3 (45.1–51.5) | 30.6 (27.6–33.8) | 10.4 (8.8–12.2) | 7.9 (6.8–9.2)
Idaho | 48.1 (44.7–51.4) | 21.5 (18.9–24.4) | 8.5 (6.6–11) | 6.3 (4.7–8.5)
Illinois | 49.2 (45.9–52.5) | 19.9 (17.1–23.0) | 8.0 (6.1–10.3) | 5.5 (4.1–7.3)
Indiana | —^f^ | —^f^ | —^f^ | —^f^
Iowa | 47.5 (44.6–50.5) | 20.1 (16.8–23.8) | 8.2 (5.3–12.3) | 6.4 (4.0–10)
Kansas | 48.6 (45.3–52.0) | 22.0 (18.9–25.5) | 8.1 (6.2–10.6) | 5.2 (3.6–7.4)
Kentucky | 53.7 (49.6–57.7) | 26.1 (22.0–30.5) | 11.1 (8.9–13.8) | 8.7 (6.9–10.8)
Louisiana | 52.0 (46.9–57.1) | 22.9 (17.7–29.1) | 8.7 (4.4–16.4) | 6.6 (3.3–12.9)
Maine | 46.3 (44.5–48.0) | 30.2 (28.9–31.6) | 9.4 (8.3–10.5) | 6.3 (5.7–7.0)
Maryland | 39.7 (38.6–40.9) | 23.0 (22.0–24.1) | 5.5 (5.0–6.0) | 3.7 (3.3–4.0)
Massachusetts | 50.7 (46.7–54.7) | 32.2 (28.4–36.3) | 11.0 (8.9–13.4) | 8.2 (6.8–9.9)
Michigan | 49.8 (46.5–53.1) | 20.8 (17.2–24.9) | 9.9 (7.3–13.4) | 7.2 (5.3–9.6)
Minnesota | —^f^ | —^f^ | —^f^ | —^f^
Mississippi | 48.3 (43.7–52.8) | 21.4 (18.2–25.0) | 6.9 (5.2–9.1 | 4.5 (3.2–6.3)
Missouri | 49.6 (43.4–55.8) | 20.7 (16.2–25.9) | 9.4 (6.6–13.3) | 6.9 (4.6–10.3)
Montana | 58.3 (55.7–61.0) | 30.2 (27.8–32.7) | 12.7 (11.2–14.3) | 8.7 (7.5–10.1)
Nebraska | 49.2 (44.7–53.7) | 17.1 (13.6–21.2) | 6.5 (4.6–9.0) | 5.1 (3.4–7.5)
Nevada | 44.5 (40.9–48.2) | 24.1 (21.2–27.3) | 6.7 (4.1–10.8) | 3.3 (1.9–5.5)
New Hampshire | 49.8 (48.4–51.2) | 33.8 (32.6–35.1) | 13.5 (12.7–14.4) | 9.5 (8.8–10.2)
New Jersey | 44.7 (39.9–49.6) | 27.6 (24.0–31.6) | 5.7 (3.9–8.3) | 3.7 (2.3–5.8)
New Mexico | 56.3 (52.7–59.9) | 34.0 (30.7–37.5) | 7.9 (6.5–9.7) | 5.6 (4.4–7.0)
New York | 42.7 (40.7–44.8) | 22.4 (20.4–24.5) | 6.4 (5.2–7.9) | 4.6 (3.5–5.9)
North Carolina | 52.4 (49.3–55.5) | 35.5 (32.5–38.5) | 11.1 (8.1–15.0) | 8.3 (5.7–12.0)
North Dakota | 52.8 (49.3–56.3) | 33.1 (29.8–36.7) | 12.1 (10.3–14.2) | 8.3 (6.8–10.2)
Ohio | 47.7 (43.4–52.1) | 29.8 (25.7–34.3) | 8.0 (5.2–12.2) | 5.3 (3.3–8.3)
Oklahoma | 57.7 (53.6–61.8) | 27.8 (23.7–32.3) | 11.4 (9.1–14.2) | 8.4 (6.7–10.5)
Oregon | —^f^ | —^f^ | —^f^ | —^f^
Pennsylvania | 52.6 (49.9–55.3) | 24.4 (21.2–27.9) | 10.0 (8.0–12.4) | 7.4 (5.8–9.4)
Rhode Island | 48.9 (45.3–52.5) | 30.1 (25.2–35.5) | 10.2 (7.2–14.3) | 7.3 (5.3–10.1)
South Carolina | 47.3 (41.5–53.2) | 21.1 (16.2–27.0) | 9.0 (6.2–12.8) | 7.0 (4.9–10.0)
South Dakota | 50.6 (44.9–56.3) | 23.9 (19.5–28.9) | 9.2 (7.1–11.7) | 5.9 (4.5–7.6)
Tennessee | 50.6 (46.2–55.0) | 22.1 (17.6–27.3) | 7.4 (5.5–9.7) | 5.5 (4.0–7.6)
Texas | 48.7 (44.9–52.5) | 18.7 (15.3–22.6) | 6.5 (4.4–9.5) | 4.8 (3.2–7.2)
Utah | 30.5 (26.0–35.5) | 9.7 (7.3–12.6) | 3.3 (2.3–4.7) | 2.4 (1.6–3.8)
Vermont | 49.8 (49.1–50.6) | 26.4 (25.7–27.1) | 11.3 (10.8–11.9) | 8.1 (7.7–8.6)
Virginia | —^f^ | 19.9 (18.1–21.9) | 6.3 (5.2–7.7) | 4.2 (3.4–5.2)
Washington | —^f^ | —^f^ | —^f^ | —^f^
West Virginia | 62.4 (57.6–67.0) | 35.7 (30.7–41.1) | 16.7 (12.3–22.3) | 12.6 (9.2–17.0)
Wisconsin | 45.5 (41.9–49.2) | 20.6 (17.0–24.8) | 8.5 (6.5–11.1) | 5.6 (4.1–7.6)
Wyoming | —^f^ | —^f^ | —^f^ | —^f^

Source: CDC (n.d.a).

Notes: CI = confidence interval.

a Includes use of e-cigarettes, e-cigars, e-pipes, vape pipes, vaping pens, e-hookahs, and hookah pens.

b Even one or two puffs.

c On at least 1 day during the 30 days before the survey.

d On 20 or more days during the 30 days before the survey.

e On all 30 days during the 30 days before the survey.

f The number of respondents within the subgroup did not meet the minimum reporting threshold or data were not available.

Table 2.32 Prevalence of ever use of e-cigarettes^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region % (95% CI) | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 28.7 (26.9–30.5) | 58.3 (51.3–65.3) | 40.4 (36.8–43.9) | 22.1 (19.5–24.8) | 7.9 (6.3–9.5)
Alaska | 25.7 (23.4–28.1) | 37.3 (28.1–46.5) | 37.1 (32.6–41.6) | 18.8 (15.5–22.1) | 7.4 (5.1–9.8)
Arizona | —^b^ | —^b^ | —^b^ | —^b^ | —^b^
Arkansas | 28.7 (26.7–30.7) | 52.1 (43.4–60.8) | 40.2 (36.1–44.3) | 23.0 (20.3–25.7) | 9.4 (7.8–11.0)
California | —^b^ | —^b^ | —^b^ | —^b^ | —^b^
Colorado | —^b^ | —^b^ | —^b^ | —^b^ | —^b^
Connecticut | 21.0 (19.5–22.4) | 46.9 (40.3–53.6) | 30.3 (27.4–33.2) | 14.9 (13.0–16.9) | 4.8 (3.5–6.0)
Delaware | 22.2 (20.2–24.3) | 39.0 (30.3–47.6) | 35.7 (31.2–40.3) | 15.7 (13.1–18.2) | 6.6 (4.7–8.6)
District of Columbia | —^b^ | —^b^ | —^b^ | —^b^ | —^b^
Florida | 23.8 (21.8–25.9) | 45.6 (37.2–54.1) | 36.2 (31.5–40.9) | 21.4 (17.8–25.1) | 7.4 (5.7–9.1)
Georgia | 26.1 (24.4–27.8) | 50.6 (43.5–57.7) | 36.2 (32.7–39.7) | 19.4 (17.1–21.7) | 8.0 (6.6–9.4)
Hawai‘i | 25.2 (23.8–26.6) | 47.9 (42.4–53.4) | 38.8 (35.9–41.7) | 18.2 (16.0–20.3) | 6.2 (4.9–7.5)
Idaho | 25.5 (23.7–27.2) | 49.0 (42.8–55.2) | 35.9 (32.5–39.4) | 18.0 (15.4–20.7) | 7.5 (5.6–9.4)
Illinois | 12.2 (10.6–13.8) | 32.8 (24.7–40.9) | 16.3 (13.3–19.3) | 8.3 (6.3–10.4) | 2.9 (1.4–4.3)
Indiana | 27.5 (26.2–28.8) | 46.6 (41.3–51.8) | 39.1 (36.4–41.8) | 22.4 (20.6–24.2) | 7.9 (6.7–9.1)
Iowa | —^b^ | —^b^ | —^b^ | —^b^ | —^b^
Kansas | 28.6 (26.9–30.3) | 51.7 (45.3–58.0) | 41.5 (38.1–44.9) | 19.9 (17.4–22.3) | 7.8 (6.2–9.4)
Kentucky | 30.4 (28.3–32.4) | 52.8 (44.8–60.9) | 45.8 (41.8–49.9) | 23.0 (20.0–25.9) | 8.7 (6.6–10.9)
Louisiana | —^b^ | —^b^ | —^b^ | —^b^ | —^b^
Maine | 19.5 (18.1–20.9) | 42.1 (35.0–49.1) | 33.4 (30.2–36.5) | 13.4 (11.8–15.1) | 5.1 (4.1–6.0)
Maryland | 19.7 (18.6–20.8) | 37.6 (32.8–42.5) | 29.7 (27.4–32.1) | 13.4 (12.1–14.7) | 5.4 (4.5–6.3)
Massachusetts | 19.1 (17.2–21.0) | 44.1 (35.7–52.4) | 28.3 (24.2–32.4) | 12.2 (9.9–14.5) | 4.5 (3.0–5.9)
Michigan | 26.6 (24.8–28.4) | 55.0 (48.6–61.3) | 37.7 (33.9–41.6) | 18.8 (16.3–21.3) | 7.7 (6.0–9.5)
Minnesota | 24.0 (23.1–24.9) | 51.7 (47.8–55.5) | 35.1 (33.3–36.9) | 15.7 (14.5–16.8) | 5.4 (4.6–6.2)
Mississippi | 23.1 (21.5–24.6) | 39.4 (32.8–45.9) | 33.6 (30.4–36.7) | 18.9 (16.7–21.1) | 5.1 (4.0–6.2)
Missouri | 27.4 (26.1–28.8) | 51.6 (46.6–56.7) | 40.3 (37.5–43.1) | 21.0 (18.9–23.0) | 7.2 (5.9–8.5)
Montana | 28.4 (26.9–29.9) | 65.2 (59.8–70.6) | 41.7 (38.6–44.9) | 18.6 (16.6–20.6) | 7.9 (6.4–9.4)
Nebraska | 24.9 (23.7–26.1) | 55.6 (51.5–59.7) | 34.6 (32.2–37.0) | 16.3 (14.7–17.9) | 4.9 (4.1–5.8)
Nevada | 28.4 (25.6–31.3) | 48.9 (38.3–59.5) | 39.0 (33.5–44.6) | 20.1 (16.0–24.2) | 11.8 (7.9–15.6)
New Hampshire | 25.2 (23.4–27.0) | 55.4 (47.5–63.3) | 42.9 (38.9–47.0) | 14.9 (13.1–16.7) | 6.2 (4.7–7.7)
New Jersey | 22.7 (21.5–23.9) | 45.3 (40.5–50.1) | 33.9 (31.5–36.3) | 15.1 (13.6–16.6) | 6.4 (5.2–7.5)
New Mexico | 29.7 (27.7–31.7) | 56.5 (49.4–63.6) | 45.2 (41.1–49.4) | 19.7 (17.1–22.4) | 8.9 (7.1–10.7)
New York | 21.0 (19.7–22.2) | 42.4 (37.2–47.7) | 30.6 (28.0–33.1) | 13.8 (12.3–15.3) | 5.8 (4.5–7.1)
North Carolina | 21.9 (20.4–23.4) | 40.3 (34.0–46.5) | 30.3 (27.3–33.4) | 19.0 (16.6–21.3) | 6.7 (5.1–8.2)
North Dakota | 25.1 (23.0–27.2) | 57.1 (49.2–65.0) | 35.9 (31.8–40.0) | 14.4 (11.8–16.9) | 4.7 (3.5–6.0)
Ohio | 28.2 (27.0–29.4) | 53.6 (48.9–58.2) | 41.1 (38.6–43.5) | 21.6 (19.9–23.2) | 7.1 (6.0–8.2)
Oklahoma | —^b^ | —^b^ | —^b^ | —^b^ | —^b^
Oregon | 21.0 (19.6–22.4) | 42.7 (37.0–48.5) | 30.3 (27.5–33.1) | 15.7 (13.7–17.7) | 6.6 (4.8–8.3)
Pennsylvania | 21.5 (19.9–23.2) | 42.7 (35.6–49.7) | 35.8 (32.2–39.4) | 13.8 (11.8–15.9) | 6.0 (4.1–7.8)
Rhode Island | 22.9 (20.9–24.8) | 49.7 (40.9–58.6) | 32.9 (28.9–36.9) | 14.9 (12.8–17.0) | 6.6 (5.1–8.2)
South Carolina | —^b^ | —^b^ | —^b^ | —^b^ | —^b^
South Dakota | 23.4 (21.0–25.8) | 60.3 (50.9–69.7) | 33.3 (28.2–38.5) | 15.1 (11.8–18.4) | 4.2 (2.8–5.6)
Tennessee | 29.8 (27.7–32.0) | 59.2 (51.0–67.5) | 42.8 (38.6–47.1) | 23.0 (20.0–26.0) | 10.1 (7.9–12.4)
Texas | 21.9 (20.1–23.6) | 42.2 (34.8–49.7) | 30.5 (27.2–33.9) | 15.0 (12.8–17.2) | 7.6 (4.8–10.4)
Utah | 24.5 (23.4–25.6) | 40.6 (37.0–44.2) | 32.5 (30.5–34.6) | 16.2 (14.5–17.9) | 5.1 (4.0–6.1)
Vermont | 21.8 (20.0–23.5) | 46.6 (38.1–55.1) | 34.7 (31.0–38.5) | 14.4 (12.6–16.3) | 5.3 (3.8–6.7)
Virginia | 24.6 (23.2–25.9) | 50.4 (44.7–56.1) | 37.0 (34.1–39.9) | 16.0 (14.2–17.7) | 6.0 (4.8–7.1)
Washington | 25.5 (24.4–26.5) | 49.6 (45.2–54.1) | 36.8 (34.6–39.0) | 18.2 (16.8–19.7) | 8.2 (7.0–9.4)
West Virginia | 28.4 (26.8–29.9) | 56.3 (49.5–63.2) | 42.4 (39.0–45.8) | 23.3 (21.1–25.5) | 8.1 (6.6–9.6)
Wisconsin | —^b^ | —^b^ | —^b^ | —^b^ | —^b^
Wyoming | 28.6 (26.4–30.9) | 61.0 (51.9–70.1) | 41.1 (36.8–45.4) | 19.5 (16.6–22.4) | 7.1 (5.6–8.6)
Region
Northeast | 21.4 (20.7–22.0) | 43.9 (41.1–46.8) | 32.5 (31.1–33.9) | 14.1 (13.3–14.9) | 5.8 (5.1–6.5)
Midwest | 23.8 (23.2–24.4) | 48.9 (46.6–51.3) | 34.1 (32.8–35.3) | 17.3 (16.5–18.1) | 6.2 (5.6–6.7)
South | 24.3 (23.7–25.0) | 46.6 (43.9–49.3) | 35.1 (33.8–36.4) | 18.6 (17.7–19.6) | 7.5 (6.7–8.2)
West | 25.5 (24.9–26.0) | 48.0 (45.9–50.2) | 36.4 (35.3–37.6) | 18.0 (17.1–18.8) | 7.8 (7.1–8.4)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes: CI = confidence interval.

a Ever e-cigarette use was defined as having used an e-cigarette or other electronic vaping product, even just one time, in one’s entire life.

b Eight states (Arizona, California, Colorado, Iowa, Louisiana, Oklahoma, South Carolina, and Wisconsin) and the District of Columbia did not field the 2020 BRFSS optional module for e-cigarettes.

In the states with available data, the state-specific prevalence of current e-cigarette use (uses e-cigarettes or other electronic vaping product every day or some days) among adults in 2020 ranged from 3.4% (95% CI, 2.5–4.2) in Illinois to 7.2% (95% CI, 6.5–7.9) in Utah (Table 2.33). The prevalence of current e-cigarette use was 0.4 percentage points (Maryland, 3.8%; 95% CI, 3.2–4.4) to 3.8 percentage points (Utah, 7.2%; 95% CI, 6.5–7.9) higher in other states (with available data) than it was in Illinois. By region, the prevalence of current e-cigarette use among adults was higher in the West (5.7%; 95% CI, 5.3–6.0) than it was in the Northeast (4.6%; 95% CI, 4.2–4.9) but was otherwise similar by region (Figure 2.17).

Table 2.33 Prevalence of current use of e-cigarettes^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region % (95% CI) | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 6.1 (5.0–7.1) | 22.7 (16.6–28.8) | 7.4 (5.5–9.3) | 2.6 (1.7–3.5) | 1.0 (0.5–1.4)
Alaska | 5.0 (3.7–6.3) | 14.9 (8.6–21.2) | 6.0 (3.5–8.5) | 2.3 (1.1–3.6) | —^b^
Arizona | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Arkansas | 5.7 (4.6–6.8) | 13.9 (8.1–19.8) | 9.1 (6.7–11.5) | 2.6 (1.6–3.6) | 1.1 (0.6–1.7)
California | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Colorado | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Connecticut | 4.5 (3.8–5.2) | 14.6 (10.4–18.8) | 5.9 (4.5–7.2) | 2.4 (1.7–3.1) | —^b^
Delaware | 4.5 (3.5–5.6) | 12.2 (6.4–18.0) | 7.2 (4.7–9.7) | 1.8 (1.0–2.6) | —^b^
District of Columbia | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Florida | 5.7 (4.5–6.9) | 14.8 (9.1–20.4) | 9.7 (6.4–13.0) | 3.5 (2.1–4.9) | —^b^
Georgia | 5.6 (4.7–6.5) | 15.7 (10.9–20.4) | 7.9 (6.1–9.7) | 2.9 (1.9–3.9) | —^b^
Hawai‘i | 5.9 (5.1–6.8) | 18.9 (14.5–23.3) | 8.8 (7.0–10.6) | 2.5 (1.6–3.5) | 0.8 (0.4–1.3)
Idaho | 6.7 (5.6–7.7) | 22.5 (17.3–27.7) | 8.2 (6.3–10.2) | 3.0 (1.8–4.2) | —^b^
Illinois | 3.4 (2.5–4.2) | 11.3 (6.3–16.4) | 4.5 (2.9–6.0) | 1.8 (0.9–2.7) | —^b^
Indiana | 5.7 (5.0–6.5) | 14.2 (10.6–17.8) | 8.5 (6.9–10.1) | 3.3 (2.5–4.0) | 0.7 (0.4–1.1)
Iowa | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Kansas | 6.6 (5.6–7.7) | 20.6 (15.4–25.8) | 8.0 (6.2–9.9) | 3.2 (2.1–4.3) | 1.1 (0.5–1.7)
Kentucky | 6.7 (5.6–7.9) | 16.0 (10.5–21.5) | 11.2 (8.6–13.8) | 3.4 (2.3–4.4) | —^b^
Louisiana | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Maine | 4.3 (3.5–5.1) | 14.0 (8.6–19.4) | 7.8 (5.9–9.7) | 1.6 (1.0–2.1) | 0.6 (0.3–0.9)
Maryland | 3.8 (3.2–4.4) | 9.4 (6.3–12.5) | 6.2 (5.0–7.5) | 1.9 (1.3–2.4) | —^b^
Massachusetts | 4.0 (3.0–5.1) | 15.7 (9.0–22.3) | 5.0 (3.0–6.9) | 1.8 (1.0–2.6) | —^b^
Michigan | 6.4 (5.4–7.5) | 21.1 (16.1–26.1) | 8.6 (6.2–11.0) | 2.9 (1.8–3.9) | —^b^
Minnesota | 4.9 (4.3–5.4) | 18.2 (15.0–21.4) | 5.9 (5.0–6.8) | 2.0 (1.6–2.4) | 0.6 (0.3–0.9)
Mississippi | 4.6 (3.8–5.5) | 13.5 (9.0–17.9) | 6.5 (4.8–8.2) | 2.5 (1.7–3.4) | —^b^
Missouri | 5.7 (5.0–6.4) | 16.1 (12.4–19.7) | 8.0 (6.5–9.5) | 3.4 (2.5–4.3) | 0.7 (0.3–1.2)
Montana | 4.9 (4.2–5.7) | 21.8 (17.1–26.5) | 5.6 (4.1–7.1) | 1.5 (0.9–2.1) | 0.8 (0.3–1.2)
Nebraska | 5.9 (5.2–6.5) | 20.9 (17.5–24.3) | 6.8 (5.5–8.1) | 2.4 (1.7–3.0) | 0.8 (0.4–1.2)
Nevada | 6.7 (4.9–8.4) | 20.8 (11.5–30.2) | 9.1 (5.7–12.5) | 2.3 (1.1–3.6) | —^b^
New Hampshire | 5.5 (4.5–6.5) | 19.9 (13.6–26.1) | 9.3 (7.0–11.6) | 1.5 (0.9–2.0) | —^b^
New Jersey | 5.0 (4.3–5.6) | 13.1 (10.1–16.0) | 7.4 (6.0–8.8) | 2.7 (1.9–3.4) | 0.8 (0.4–1.2)
New Mexico | 5.6 (4.4–6.7) | 17.6 (12.1–23.1) | 7.8 (5.3–10.3) | 2.3 (1.3–3.3) | —^b^
New York | 4.1 (3.5–4.7) | 10.6 (7.3–13.8) | 5.2 (4.1–6.3) | 2.7 (1.9–3.5) | 1.1 (0.6–1.6)
North Carolina | 4.7 (3.9–5.4) | 13.9 (9.5–18.2) | 5.6 (4.2–7.0) | 3.5 (2.5–4.6) | —^b^
North Dakota | 4.5 (3.5–5.5) | 10.8 (6.2–15.5) | 7.2 (5.0–9.4) | 1.9 (0.9–2.9) | —^b^
Ohio | 6.0 (5.3–6.7) | 19.0 (15.4–22.5) | 7.8 (6.5–9.2) | 3.3 (2.6–4.1) | —^b^
Oklahoma | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Oregon | 4.5 (3.8–5.2) | 14.1 (10.0–18.1) | 6.1 (4.7–7.6) | 2.7 (1.8–3.6) | 0.8 (0.3–1.2)
Pennsylvania | 5.3 (4.4–6.2) | 15.1 (10.4–19.8) | 8.1 (6.1–10.2) | 2.8 (1.8–3.7) | —^b^
Rhode Island | 4.6 (3.5–5.6) | 13.2 (7.5–18.9) | 7.2 (4.9–9.5) | 1.8 (1.1–2.6) | —^b^
South Carolina | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
South Dakota | 3.9 (2.8–5.1) | 13.8 (6.9–20.7) | 4.8 (2.7–6.9) | 2.0 (0.9–3.1) | —^b^
Tennessee | 6.9 (5.6–8.3) | 29.1 (20.0–38.3) | 8.0 (5.8–10.2) | 3.6 (2.3–4.8) | —^b^
Texas | 4.7 (3.8–5.5) | 9.4 (5.6–13.3) | 6.7 (4.9–8.6) | 2.8 (1.9–3.8) | —^b^
Utah | 7.2 (6.5–7.9) | 17.6 (14.7–20.4) | 8.9 (7.6–10.2) | 3.0 (2.3–3.8) | —^b^
Vermont | 4.0 (3.1–5.0) | 12.2 (6.3–18.1) | 5.9 (4.0–7.7) | 2.2 (1.4–3.1) | —^b^
Virginia | 5.2 (4.4–5.9) | 14.8 (11.0–18.5) | 7.7 (6.0–9.3) | 2.4 (1.7–3.2) | —^b^
Washington | 5.2 (4.6–5.8) | 13.2 (10.5–16.0) | 7.5 (6.3–8.7) | 3.0 (2.3–3.6) | 1.4 (0.8–2.0)
West Virginia | 6.3 (5.3–7.3) | 23.1 (16.9–29.3) | 9.2 (7.2–11.2) | 2.7 (1.8–3.5) | 0.9 (0.4–1.4)
Wisconsin | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Wyoming | 5.9 (4.7–7.1) | 18.3 (11.6–25.0) | 8.4 (6.0–10.9) | 2.4 (1.3–3.5) | —^b^
Region
Northeast | 4.6 (4.2–4.9) | 13.0 (11.2–14.8) | 6.4 (5.7–7.1) | 2.5 (2.1–2.9) | 0.9 (0.6–1.1)
Midwest | 5.3 (5.0–5.7) | 16.9 (15.2–18.6) | 7.1 (6.4–7.8) | 2.7 (2.4–3.1) | 0.7 (0.5–0.8)
South | 5.3 (4.9–5.6) | 14.4 (12.7–16.1) | 7.7 (6.9–8.4) | 3.0 (2.6–3.3) | 1.1 (0.8–1.3)
West | 5.7 (5.3–6.0) | 16.7 (15.1–18.4) | 7.7 (7.0–8.4) | 2.7 (2.4–3.0) | 1.1 (0.8–1.3)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes: CI = confidence interval.

a Current use of e-cigarettes was defined as having ever used such products and using them every day or some days at the time of the survey.

b Estimate is not presented because of a relative standard error >30%.

c Eight states (Arizona, California, Colorado, Iowa, Louisiana, Oklahoma, South Carolina, and Wisconsin) and the District of Columbia did not field the 2020 BRFSS optional module for e-cigarettes.

Consistent with earlier findings (Delnevo et al. 2016), young adults had the highest prevalence of ever e-cigarette use among all age groups and across all states with available data. In 2020, the state-specific prevalence of ever use of e-cigarettes among young adults ranged from 32.8% (95% CI, 24.7–40.9) in Illinois to 65.2% (95% CI, 59.8–70.6) in Montana (Table 2.32). The prevalence of ever e-cigarette use among young adults was 4.5 percentage points (Alaska, 37.3%; 95% CI, 28.1–46.5) to 32.4 percentage points (Montana, 65.2%; 95% CI, 59.8–70.6) higher in other states (with available data) than it was in Illinois. By region, ever use of e-cigarettes among young adults ranged from 43.9% (95% CI, 41.1–46.8) in the Northeast to 48.9% (95% CI, 46.6–51.3) in the Midwest.

Among states with available data, the state-specific prevalence of current e-cigarette use among young adults in 2020 ranged from 9.4% in Maryland (95% CI, 6.3–12.5) and Texas (95% CI, 5.6–13.3) to 29.1% (95% CI, 20.0–38.3) in Tennessee (Table 2.33). The prevalence of current e-cigarette use among young adults was 1.2 percentage points (New York, 10.6%; 95% CI, 7.3–13.8) to 19.7 percentage points (Tennessee, 29.1%; 95% CI, 20.0–38.3) higher in other states (with available data) than it was in Maryland and Texas. By region, the prevalence of current e-cigarette use among young adults was lower in the Northeast (13.0%; 95% CI, 11.2–14.8) than it was in the West (16.7%; 95% CI, 15.1–18.4) and the Midwest (16.9%; 95% CI, 15.2–18.6); the prevalence of current e-cigarette use among young adults was 14.4% (95% CI, 12.7–16.1) in the South.

Daily Versus Non-Daily Use of E-Cigarettes. Among states with available data, daily use of e-cigarettes among adults in 2020 ranged from 1.2% (95% CI, 0.7–1.8) in Illinois to 3.6% (95% CI, 3.1–4.1) in Utah (Table 2.34). The prevalence of non-daily e-cigarette use was higher than daily use of e-cigarettes among adults in all states. Among states with available data, the prevalence of non-daily e-cigarette use among adults ranged from 2.0% (95% CI, 1.4–2.6) in Vermont to 4.2% (95% CI, 3.3–5.0) in West Virginia (Table 2.35). The prevalence of daily and non-daily e-cigarette use was similar across regions, and non-daily use of e-cigarettes was higher than daily use in each of the four regions.

Figure 2.17 Prevalence of current use of e-cigarettes^a^ a Current use of e-cigarettes was defined as having ever used such products and using them every day or some days at the time of the survey. among adults, 18 years of age and older, by region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Notes:CI = confidence interval.

In 2020, the prevalence of current e-cigarette use among adults was higher in the West (5.7%) than it was in the Northeast (4.6%). The prevalence of current e-cigarette use among adults was 5.3% in the Midwest and South.

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Table 2.34 Prevalence of daily use of e-cigarettes^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2018, United States

Location and region % (95% CI) | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 2.7 (2.0–3.5) | 9.6 (4.9–14.2) | 3.2 (1.9–4.5) | 1.4 (0.8–2.0) | 0.6 (0.3–1.0)
Alaska | 1.7 (0.9–2.4) | —^b^ | —^b^ | —^b^ | —^b^
Arizona | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Arkansas | 2.8 (2.0–3.5) | 7.2 (3.2–11.1) | 4.2 (2.7–5.8) | 1.4 (0.6–2.1) | —^b^
California | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Colorado | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Connecticut | 1.8 (1.3–2.3) | 6.3 (3.2–9.4) | 1.9 (1.2–2.7) | 1.2 (0.7–1.7) | —^b^
Delaware | 1.8 (1.2–2.5) | —^b^ | 3.4 (1.9–5.0) | —^b^ | —^b^
District of Columbia | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Florida | 2.3 (1.6–3.0) | 8.0 (3.4–12.6) | 2.8 (1.4–4.1) | —^b^ | —^b^
Georgia | 2.5 (1.9–3.1) | 6.3 (3.0–9.6) | 3.6 (2.4–4.8) | 1.4 (0.7–2.1) | —^b^
Hawai‘i | 3.4 (2.7–4.1) | 9.2 (5.8–12.7) | 5.4 (3.9–7.0) | 1.6 (0.7–2.5) | —^b^
Idaho | 3.4 (2.6–4.1) | 12.0 (7.9–16.2) | 4.0 (2.6–5.3) | —^b^ | —^b^
Illinois | 1.2 (0.7–1.8) | —^b^ | —^b^ | —^b^ | —^b^
Indiana | 2.8 (2.3–3.3) | 7.2 (4.5–10.0) | 4.2 (3.0–5.4) | 1.5 (1.0–2.0) | —^b^
Iowa | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Kansas | 2.9 (2.2–3.5) | 7.5 (4.3–10.7) | 3.5 (2.3–4.7) | 1.7 (0.8–2.6) | —^b^
Kentucky | 2.8 (2.1–3.5) | 5.7 (2.5–9.0) | 5.1 (3.3–6.8) | 1.3 (0.7–1.8) | —^b^
Louisiana | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Maine | 1.9 (1.3–2.5) | 7.9 (3.3–12.4) | 2.8 (1.6–3.9) | 0.7 (0.3–1.0)
Maryland | 1.7 (1.3–2.0) | 3.0 (1.3–4.7) | 3.1 (2.1–4.1) | 0.8 (0.4–1.1) | —^b^
Massachusetts | 1.4 (0.8–2.0) | —^b^ | —^b^ | —^b^ | —^b^
Michigan | 3.1 (2.3–3.8) | 10.2 (6.5–14.0) | 4.1 (2.4–5.9) | 1.3 (0.6–2.0) | —^b^
Minnesota | 2.2 (1.8–2.5) | 6.4 (4.5–8.3) | 3.0 (2.3–3.7) | 1.0 (0.7–1.2) | —^b^
Mississippi | 2.0 (1.4–2.6) | 4.8 (2.2–7.4) | 2.9 (1.7–4.1) | 1.3 (0.6–1.9) | —^b^
Missouri | 2.5 (2.0–2.9) | 6.4 (4.0–8.8) | 3.5 (2.5–4.5) | 1.6 (0.9–2.2) | —^b^
Montana | 2.0 (1.5–2.4) | 7.7 (4.6–10.8) | 2.1 (1.2–3.0) | 1.0 (0.5–1.5) | —^b^
Nebraska | 2.6 (2.1–3.1) | 9.9 (7.3–12.5) | 2.8 (1.9–3.6) | 1.0 (0.5–1.4) | —^b^
Nevada | 2.7 (1.5–3.9) | —^b^ | —^b^ | —^b^ | —^b^
New Hampshire | 2.5 (1.8–3.2) | 8.7 (4.4–13.0) | 4.3 (2.7–5.9) | —^b^ | —^b^
New Jersey | 2.1 (1.7–2.6) | 4.1 (2.5–5.7) | 3.7 (2.6–4.8) | 1.1 (0.5–1.7) | —^b^
New Mexico | 1.9 (1.2–2.7) | —^b^ | 3.3 (1.5–5.1) | 0.7 (0.3–1.1) | —^b^
New York | 1.8 (1.4–2.2) | 5.0 (2.4–7.6) | 2.2 (1.5–2.9) | 1.1 (0.6–1.7) | —^b^
North Carolina | 2.0 (1.5–2.5) | 7.0 (3.6–10.4) | 2.3 (1.4–3.2) | 1.5 (0.8–2.1) | —^b^
North Dakota | 2.2 (1.5–2.9) | 6.3 (2.6–9.9) | 3.1 (1.6–4.6) | —^b^ | —^b^
Ohio | 2.9 (2.4–3.4) | 9.9 (7.1–12.6) | 3.5 (2.5–4.6) | 1.4 (1.0–1.9) | —^b^
Oklahoma | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Oregon | 2.0 (1.5–2.5) | 6.5 (3.4–9.6) | 2.4 (1.5–3.4) | 1.3 (0.8–1.9) | —^b^
Pennsylvania | 2.1 (1.6–2.6) | 6.9 (3.8–9.9) | 2.9 (1.7–4.0) | 1.1 (0.5–1.8) | —^b^
Rhode Island | 2.1 (1.3–2.8) | —^b^ | 3.6 (1.9–5.4) | —^b^ | —^b^
South Carolina | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
South Dakota | 1.8 (1.1–2.5) | —^b^ | —^b^ | —^b^ | —^b^
Tennessee | 3.4 (2.3–4.5) | —^b^ | 4.4 (2.6–6.1) | 1.8 (0.8–2.7) | —^b^
Texas | 2.2 (1.6–2.9) | —^b^ | 4.2 (2.6–5.7) | 1.2 (0.6–1.9) | —^b^
Utah | 3.6 (3.1–4.1) | 8.1 (6.1–10.1) | 4.9 (3.9–5.8) | 1.3 (0.8–1.9) | —^b^
Vermont | 2.0 (1.2–2.8) | —^b^ | 2.3 (1.0–3.6) | 1.1 (0.5–1.8) | —^b^
Virginia | 2.4 (1.8–2.9) | 6.1 (3.6–8.7) | 3.9 (2.7–5.1) | 1.0 (0.5–1.6) | —^b^
Washington | 2.4 (2.0–2.7) | 5.8 (3.8–7.7) | 3.5 (2.6–4.3) | 1.3 (0.9–1.8) | —^b^
West Virginia | 2.2 (1.6–2.7) | 7.0 (3.5–10.6) | 3.2 (2.0–4.4) | 0.9 (0.4–1.4) | —^b^
Wisconsin | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Wyoming | 2.8 (2.0–3.7) | 7.8 (3.4–12.2) | 4.5 (2.7–6.3) | —^b^ | —^b^
Region
Northeast | 1.9 (1.7–2.2) | 5.6 (4.3–6.9) | 2.6 (2.2–3.1) | 1.1 (0.8–1.3) | 0.4 (0.2–0.6)
Midwest | 2.4 (2.2–2.6) | 7.9 (6.7–9.2) | 3.2 (2.7–3.7) | 1.1 (0.9–1.3) | 0.3 (0.2–0.4)
South | 2.4 (2.1–2.6) | 5.7 (4.6–6.8) | 3.6 (3.1–4.1) | 1.3 (1.1–1.6) | 0.6 (0.4–0.8)
West | 2.5 (2.3–2.8) | 7.2 (6.1–8.2) | 3.6 (3.1–4.0) | 1.2 (1.0–1.5) | 0.5 (0.3–0.6)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes: CI = confidence interval.

a Daily use of e-cigarettes was defined as having ever used such products and using them every day at the time of the survey.

b Estimate is not presented because of a relative standard error >30%.

c Eight states (Arizona, California, Colorado, Iowa, Louisiana, Oklahoma, South Carolina, and Wisconsin) and the District of Columbia

Many estimates of daily e-cigarette use among young adults in 2020 were suppressed due to a relative standard error greater than or equal to 30.0%. Available estimates ranged from 3.0% (95% CI, 1.3–4.7) in Maryland to 12.0% (95% CI, 7.9–16.2) in Idaho (Table 2.34). Generally, the prevalence of non-daily e-cigarette use among young adults was higher than the prevalence of daily use (Table 2.35). Among states with available data, the prevalence of non-daily e-cigarette use among young adults ranged from 5.6% (95% CI, 3.4–7.7) in New York to 16.6% (95% CI, 9.7–23.6) in Tennessee (Table 2.35). By region, the prevalence of daily e-cigarette use among young adults ranged from 5.6% (95% CI, 4.3–6.9) in the Northeast to 7.9% (95% CI, 6.7–9.2) in the Midwest, and non-daily use ranged from 7.4% (95% CI, 6.1–8.8) in the Northeast to 9.6% (95% CI, 8.3–10.9) in the West.

##### Smokeless Tobacco Use

Youth. For the 37 states with available data, past-30-day use of smokeless tobacco (chewing tobacco, snuff, dip, snus, or dissolvable tobacco products) among U.S. high school students in 2019 ranged from 1.7% (95% CI, 1.1–2.6) in Utah to 10.0% (95% CI, 5.8–16.6) in Alaska (Table 2.36). The prevalence of past-30-day smokeless tobacco use was 0.8 percentage points (Arizona, 2.5%; 95% CI, 2.0–3.3) to 8.3 percentage points (Alaska, 10.0%; 95% CI, 5.8–16.6) higher in other states (with available data) than it was in Utah.

Adults. The state-specific prevalence of current smokeless tobacco use (defined has having used chewing tobacco, snuff, or snus every day or some days) among all adults (18 years of age and older) in 2020 ranged from 0.8% (95% CI, 0.5–1.1) in Rhode Island to 8.9% (95% CI, 7.6–10.2) in Wyoming (Table 2.37). The prevalence of current smokeless tobacco use among adults was 0.7 percentage points (Massachusetts, 1.5%; 95% CI, 1.1–2.0) to 8.1 percentage points (Wyoming, 8.9%; 95% CI, 7.9–10.2) higher in other states than it was in Rhode Island. By region, current use of smokeless tobacco among all adults was highest in the South (3.9%; 95% CI, 3.7–4.2) and Midwest (3.7%; 95% CI, 3.5–3.9), followed by the West (2.7%; 95% CI, 2.4–2.9) and the Northeast (2.4%; 95% CI, 2.2–2.6) (Figure 2.18).

For states with available data, the state-specific prevalence of current use of smokeless tobacco among young adults in 2020 ranged from 1.9% (95% CI, 0.9–3.0) in New York to 10.5% (95% CI, 7.4–13.7) in Montana (Table 2.37). The prevalence of current smokeless tobacco use among young adults was 0.1 percentage points (New Jersey, 2.0%; 95% CI, 0.8–3.1) to 8.6 percentage points (Montana, 10.5%; 95% CI, 7.4–13.7) higher in other states (with available data) than it was in New York. By region, the prevalence of current smokeless tobacco use among young adults was similar across all four regions, ranging from 2.7% (95% CI, 1.9–3.5) in the Northeast to 4.1% (95% CI, 3.4–4.8) in the South.

Daily Versus Non-Daily Smokeless Tobacco Use. The prevalence of daily use of smokeless tobacco among adults in 2020 ranged from 0.3% (95% CI, 0.1–0.6) in the District of Columbia to 5.8% (95% CI, 4.9–6.6) in West Virginia (Table 2.38); non-daily use of smokeless tobacco ranged from 0.4% (95% CI, 0.2–0.6) in Rhode Island to 3.4% (95% CI, 2.6–4.1) in Oklahoma and Wyoming (Table 2.39). Both daily and non-daily use of smokeless tobacco were similar by region, with daily use ranging from 1.2% (95% CI, 1.0–1.3) in the Northeast to 2.2% (95% CI, 2.1–2.4) in the South, and non-daily use ranging from 1.2% (95% CI, 1.1–1.4) in both the Northeast and the West to 1.7% (95% CI, 1.6–1.9) in the South.

Table 2.35 Prevalence of nondaily use of e-cigarettes^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region % (95% CI) | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 3.3 (2.6–4.1) | 13.1 (8.5–17.7) | 4.2 (2.7–5.7) | 1.2 (0.6–1.9) | —^b^
Alaska | 3.3 (2.3–4.4) | 11.9 (6.2–17.6) | 3.5 (1.6–5.5) | —^b^ | —^b^
Arizona | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Arkansas | 2.9 (2.1–3.8) | —^b^ | 4.8 (3.0–6.7) | 1.3 (0.6–1.9) | —^b^
California | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Colorado | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Connecticut | 2.6 (2.1–3.2) | 8.3 (5.3–11.3) | 3.9 (2.8–5.0) | 1.3 (0.8–1.8) | —^b^
Delaware | 2.7 (1.8–3.6) | —^b^ | 3.8 (1.8–5.8) | 1.2 (0.6–1.9) | —^b^
District of Columbia | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Florida | 3.4 (2.4–4.3) | 6.7 (3.2–10.3) | 6.9 (3.9–10.0) | 1.8 (1.0–2.6) | —^b^
Georgia | 3.1 (2.4–3.8) | 9.3 (5.7–13.0) | 4.3 (2.9–5.7) | 1.5 (0.8–2.2) | —^b^
Hawai‘i | 2.6 (2.1–3.1) | 9.7 (6.5–12.8) | 3.4 (2.5–4.4) | 0.9 (0.5–1.4) | —^b^
Idaho | 3.3 (2.6–4.0) | 10.4 (6.8–14.1) | 4.3 (2.8–5.8) | 1.6 (0.7–2.5) | —^b^
Illinois | 2.1 (1.5–2.7) | 5.9 (2.6–9.2) | 2.8 (1.6–4.0) | 1.5 (0.6–2.3) | —^b^
Indiana | 2.9 (2.4–3.5) | 6.9 (4.4–9.5) | 4.3 (3.2–5.4) | 1.8 (1.3–2.3) | —^b^
Iowa | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Kansas | 3.8 (2.9–4.6) | 13.1 (8.6–17.6) | 4.5 (3.0–6.0) | 1.5 (0.8–2.2) | —^b^
Kentucky | 3.9 (3.0–4.8) | 10.3 (5.7–14.9) | 6.2 (4.2–8.2) | 2.1 (1.2–3.0) | —^b^
Louisiana | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Maine | 2.4 (1.8–3.0) | 6.1 (2.7–9.4) | 5.1 (3.5–6.7) | 0.9 (0.5–1.3) | —^b^
Maryland | 2.1 (1.7–2.6) | 6.3 (3.6–9.0) | 3.1 (2.3–3.9) | 1.1 (0.7–1.5) | —^b^
Massachusetts | 2.7 (1.8–3.6) | 10.8 (4.7–17.0) | 3.2 (1.8–4.6) | 1.1 (0.5–1.8) | —^b^
Michigan | 3.4 (2.6–4.2) | 10.9 (7.1–14.6) | 4.5 (2.8–6.3) | 1.6 (0.8–2.4) | —^b^
Minnesota | 2.7 (2.3–3.1) | 11.8 (9.0–14.5) | 2.9 (2.2–3.5) | 1.0 (0.8–1.3) | —^b^
Mississippi | 2.6 (2.0–3.3) | 8.6 (4.9–12.4) | 3.6 (2.3–4.8) | 1.3 (0.7–1.8) | —^b^
Missouri | 3.3 (2.7–3.8) | 9.7 (6.7–12.7) | 4.5 (3.3–5.7) | 1.8 (1.2–2.4) | —^b^
Montana | 3.0 (2.4–3.6) | 14.1 (10.2–18.0) | 3.5 (2.3–4.8) | —^b^ | —^b^
Nebraska | 3.2 (2.7–3.8) | 11.0 (8.5–13.5) | 4.0 (3.0–5.0) | 1.4 (0.8–2.0) | —^b^
Nevada | 4.0 (2.7–5.4) | —^b^ | 5.7 (3.4–8.0) | —^b^ | —^b^
New Hampshire | 3.0 (2.2–3.8) | 11.1 (6.2–16.1) | 5.0 (3.3–6.7) | 0.8 (0.3–1.2) | —^b^
New Jersey | 2.8 (2.4–3.3) | 9.0 (6.4–11.5) | 3.7 (2.7–4.6) | 1.6 (1.1–2.1) | —^b^
New Mexico | 3.6 (2.7–4.5) | 13.1 (8.3–17.9) | 4.5 (2.7–6.3) | 1.6 (0.7–2.6) | —^b^
New York | 2.3 (1.8–2.7) | 5.6 (3.4–7.7) | 3.0 (2.1–3.8) | 1.5 (0.9–2.1) | —^b^
North Carolina | 2.7 (2.1–3.2) | 6.8 (3.9–9.8) | 3.3 (2.3–4.4) | 2.1 (1.3–2.9) | —^b^
North Dakota | 2.3 (1.6–3.0) | —^b^ | 4.1 (2.5–5.8) | —^b^ | —^b^
Ohio | 3.1 (2.6–3.6) | 9.1 (6.5–11.7) | 4.3 (3.3–5.2) | 1.9 (1.3–2.5) | —^b^
Oklahoma | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Oregon | 2.5 (2.0–3.1) | 7.6 (4.7–10.4) | 3.7 (2.5–4.8) | 1.4 (0.7–2.0) | —^b^
Pennsylvania | 3.2 (2.5–3.9) | 8.2 (4.5–12.0) | 5.3 (3.5–7.0) | 1.7 (1.0–2.4) | —^b^
Rhode Island | 2.5 (1.8–3.3) | 7.8 (3.2–12.3) | 3.6 (2.1–5.1) | 1.2 (0.6–1.9) | —^b^
South Carolina | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
South Dakota | 2.2 (1.3–3.1) | —^b^ | 3.0 (1.4–4.6) | —^b^ | —^b^
Tennessee | 3.5 (2.6–4.4) | 16.6 (9.7–23.6) | 3.7 (2.3–5.1) | 1.8 (1.0–2.6) | —^b^
Texas | 2.4 (1.8–3.1) | 7.7 (4.0–11.4) | 2.6 (1.6–3.5) | 1.6 (0.9–2.3) | —^b^
Utah | 3.6 (3.1–4.1) | 9.5 (7.3–11.7) | 4.0 (3.1–4.9) | 1.7 (1.1–2.3) | —^b^
Vermont | 2.0 (1.4–2.6) | —^b^ | 3.6 (2.2–4.9) | 1.1 (0.5–1.6) | —^b^
Virginia | 2.8 (2.2–3.4) | 8.6 (5.7–11.6) | 3.8 (2.6–5.0) | 1.4 (0.8–1.9) | —^b^
Washington | 2.8 (2.4–3.3) | 7.4 (5.4–9.5) | 4.0 (3.2–4.9) | 1.6 (1.2–2.1) | 0.8 (0.3–1.2)
West Virginia | 4.2 (3.3–5.0) | 16.1 (10.5–21.7) | 6.0 (4.3–7.6) | 1.7 (1.1–2.4) | —^b^
Wisconsin | —^c^ | —^c^ | —^c^ | —^c^ | —^c^
Wyoming | 3.1 (2.2–4.0) | 10.5 (5.1–15.9) | 3.9 (2.2–5.7) | 1.5 (0.6–2.3) | —^b^
Region
Northeast | 2.6 (2.4–2.9) | 7.4 (6.1–8.8) | 3.8 (3.2–4.3) | 1.5 (1.2–1.7) | 0.5 (0.3–0.7)
Midwest | 2.9 (2.7–3.1) | 9.0 (7.8–10.2) | 3.9 (3.4–4.4) | 1.6 (1.3–1.9) | 0.3 (0.2–0.4)
South | 2.9 (2.7–3.2) | 8.7 (7.3–10.1) | 4.1 (3.5–4.7) | 1.6 (1.4–1.9) | 0.5 (0.3–0.6)
West | 3.1 (2.9–3.4) | 9.6 (8.3–10.9) | 4.1 (3.7–4.6) | 1.5 (1.2–1.7) | 0.6 (0.4–0.8)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes: CI = confidence interval.

a Nondaily use of e-cigarettes was defined as having ever used such products and using them some days at the time of the survey.

b Estimate is not presented because of a relative standard error >30%.

c Eight states (Arizona, California, Colorado, Iowa, Louisiana, Oklahoma, South Carolina, and Wisconsin) and the District of Columbia did not field the 2020 BRFSS optional module for e-cigarettes.

Table 2.36 Prevalence of smokeless tobacco use^a^ among high school students, by location; national Youth Risk Behavior Survey (YRBS) 2019, United States

Location | Past-30-day use:^b^ % (95% CI)
Alabama | 8.9 (6.5–12.0)
Alaska | 10.0 (5.8–16.6)
Arizona | 2.5 (2.0–3.3)
Arkansas | 7.3 (5.9–9.1)
California | 7.6 (3.3–16.5)
Colorado | —^c^
Connecticut | 2.6 (1.6–4.2)
Delaware | —^c^
District of Columbia | —^c^
Florida | —^c^
Georgia | 5.3 (4.1–6.7)
Hawai‘i | —^c^
Idaho | 3.4 (2.3–5.0)
Illinois | 4.1 (3.3–5.1)
Indiana | —^c^
Iowa | 4.9 (4.0–5.9)
Kansas | 4.5 (2.9–7.2)
Kentucky | 6.4 (4.7–8.7)
Louisiana | 5.8 (4.1–8.2)
Maine | 4.0 (3.4–4.6)
Maryland | 4.6 (4.1–5.2)
Massachusetts | 4.8 (3.4–6.5)
Michigan | 2.9 (2.2–3.7)
Minnesota | —^c^
Mississippi | 6.5 (5.1–8.2)
Missouri | 5.5 (4.0–7.4)
Montana | 6.3 (5.3–7.3)
Nebraska | 3.6 (2.5–5.1)
Nevada | 3.8 (2.9–4.9)
New Hampshire | —^c^
New Jersey | —^c^
New Mexico | 5.9 (4.9–7.0)
New York | —^c^
North Carolina | —^c^
North Dakota | 4.5 (3.4–5.8)
Ohio | 9.9 (4.7–19.6)
Oklahoma | 5.7 (4.4–7.5)
Oregon | —^c^
Pennsylvania | 3.9 (2.9–5.4)
Rhode Island | 2.5 (1.7–3.7)
South Carolina | 7.1 (5.3–9.6)
South Dakota | 7.1 (5.0–10.1)
Tennessee | 8.2 (5.4–12.4)
Texas | 3.4 (2.2–5.1)
Utah | 1.7 (1.1–2.6)
Vermont | 3.5 (3.2–3.8)
Virginia | 3.8 (3.0–4.8)
Washington | —^c^
West Virginia | 9.5 (7.5–12.0)
Wisconsin | 3.3 (2.3–4.6)
Wyoming | —^c^

Source: CDC (n.d.a).

Notes: CI = confidence interval.

a Includes use of chewing tobacco, snuff, dip, snus, or dissolvable tobacco products.

b On at least 1 day during the 30 days before the survey.

c The number of respondents within the subgroup did not meet the minimum reporting threshold or data were not available.

Table 2.37 Prevalence of current use of smokeless tobacco products^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 5.7 (4.8–6.6) | 4.7 (2.0–7.5) | 6.8 (5.0–8.5) | 6.3 (4.7–7.8) | 3.9 (2.6–5.2)
Alaska | 7.2 (5.9–8.5) | 7.2 (3.1–11.2) | 8.9 (6.2–11.6) | 6.6 (4.8–8.4) | 4.9 (2.7–7.0)
Arizona | 3.0 (2.4–3.5) | 4.8 (2.6–7.0) | 3.6 (2.6–4.5) | 3.1 (2.3–4.0) | 1.0 (0.5–1.4)
Arkansas | 6.8 (5.7–7.9) | 9.5 (4.5–14.5) | 6.7 (4.8–8.6) | 7.8 (5.9–9.6) | 4.2 (3.1–5.4)
California | 1.8 (1.3–2.3) | —^b^ | 2.2 (1.3–3.2) | 1.5 (0.7–2.3) | —^b^
Colorado | 3.6 (3.1–4.1) | 4.0 (2.4–5.5) | 4.7 (3.7–5.7) | 3.5 (2.8–4.3) | 1.5 (1.0–2.0)
Connecticut | 1.7 (1.3–2.1) | 2.7 (1.1–4.2) | 1.9 (1.1–2.7) | 1.7 (1.0–2.4) | —^b^
Delaware | 2.4 (1.6–3.2) | —^b^ | 3.6 (1.8–5.3) | 1.5 (0.9–2.2) | —^b^
District of Columbia | 1.8 (1.1–2.6) | —^b^ | 2.2 (1.0–3.4) | —^b^ | —^b^
Florida | 2.3 (1.8–2.8) | 2.1 (0.9–3.4) | 1.9 (1.1–2.6) | 3.7 (2.4–4.9) | 1.1 (0.6–1.6)
Georgia | 3.6 (2.9–4.3) | —^b^ | 4.6 (3.1–6.0) | 2.9 (2.1–3.8) | 2.7 (2.0–3.4)
Hawai‘i | 2.3 (1.8–2.8) | —^b^ | 3.3 (2.2–4.3) | 2.1 (1.4–2.9) | 1.0 (0.5–1.5)
Idaho | 5.2 (4.3–6.0) | 5.4 (2.9–7.9) | 6.9 (5.1–8.8) | 5.3 (3.8–6.8) | 2.2 (1.4–2.9)
Illinois | 1.8 (1.3–2.4) | —^b^ | 2.2 (1.0–3.3) | 1.9 (1.0–2.8) | —^b^
Indiana | 4.6 (4.0–5.2) | 3.7 (1.8–5.5) | 6.3 (4.9–7.7) | 4.6 (3.7–5.5) | 2.5 (1.8–3.2)
Iowa | 4.4 (3.9–4.9) | 5.4 (3.4–7.5) | 5.6 (4.6–6.7) | 4.6 (3.8–5.4) | 1.9 (1.3–2.4)
Kansas | 5.2 (4.6–5.8) | 4.5 (2.7–6.3) | 6.9 (5.8–8.1) | 5.6 (4.6–6.5) | 2.5 (1.8–3.2)
Kentucky | 6.1 (5.1–7.1) | 4.2 (1.9–6.5) | 8.3 (6.1–10.5) | 6.1 (4.5–7.7) | 3.9 (2.3–5.5)
Louisiana | 5.5 (4.6–6.5) | 6.4 (2.6–10.1) | 6.4 (4.6–8.2) | 6.1 (4.5–7.7) | 2.8 (1.7–4.0)
Maine | 2.7 (2.1–3.3) | —^b^ | 4.9 (3.4–6.4) | 2.0 (1.3–2.7) | 1.2 (0.7–1.7)
Maryland | 1.7 (1.3–2.1) | —^b^ | 2.2 (1.5–3.0) | 1.7 (1.0–2.3) | 0.7 (0.4–1.0)
Massachusetts | 1.5 (1.1–2.0) | —^b^ | 1.8 (1.0–2.7) | 1.3 (0.8–1.7) | —^b^
Michigan | 2.9 (2.3–3.4) | —^b^ | 4.6 (3.3–5.8) | 2.5 (1.7–3.3) | 1.5 (0.8–2.3)
Minnesota | 3.7 (3.3–4.1) | 4.3 (3.0–5.7) | 4.9 (4.1–5.7) | 3.7 (3.1–4.3) | 1.6 (1.1–2.1)
Mississippi | 7.1 (6.2–8.0) | —^b^ | 8.0 (6.2–9.7) | 8.1 (6.6–9.5) | 5.8 (4.6–7.0)
Missouri | 4.9 (4.3–5.5) | 4.0 (2.3–5.8) | 6.7 (5.4–8.1) | 5.3 (4.2–6.3) | 2.2 (1.5–2.9)
Montana | 8.0 (7.2–8.8) | 10.5 (7.4–13.7) | 10.7 (8.9–12.5) | 7.7 (6.3–9.0) | 3.8 (2.9–4.8)
Nebraska | 5.2 (4.6–5.7) | 4.7 (3.3–6.1) | 7.7 (6.4–9.0) | 5.1 (4.2–5.9) | 1.7 (1.2–2.1)
Nevada | 3.0 (2.2–3.8) | —^b^ | 3.2 (1.8–4.6) | 3.9 (2.2–5.5) | —^b^
New Hampshire | 1.8 (1.3–2.3) | —^b^ | 2.5 (1.3–3.8) | 1.6 (1.0–2.3) | —^b^
New Jersey | 1.5 (1.2–1.9) | 2.0 (0.8–3.1) | 2.2 (1.4–3.0) | 1.3 (0.9–1.7) | —^b^
New Mexico | 3.6 (2.9–4.3) | —^b^ | 4.6 (3.1–6.1) | 4.1 (2.9–5.4) | 2.0 (1.2–2.8)
New York | 2.1 (1.8–2.5) | 1.9 (0.9–3.0) | 2.6 (1.9–3.2) | 2.4 (1.7–3.2) | 1.1 (0.5–1.6)
North Carolina | 3.9 (3.2–4.5) | 3.3 (1.5–5.0) | 4.8 (3.5–6.1) | 4.3 (3.1–5.5) | 2.3 (1.4–3.2)
North Dakota | 6.3 (5.3–7.3) | 6.5 (3.2–9.9) | 8.7 (6.5–10.8) | 6.3 (4.6–8.0) | 2.4 (1.6–3.2)
Ohio | 4.2 (3.7–4.6) | 3.3 (1.9–4.7) | 6.2 (5.1–7.2) | 4.1 (3.4–4.9) | 1.9 (1.4–2.5)
Oklahoma | 7.1 (6.1–8.0) | 6.0 (2.9–9.1) | 8.5 (6.5–10.5) | 7.4 (6.0–8.9) | 4.9 (3.7–6.2)
Oregon | 3.7 (3.1–4.4) | 5.0 (2.5–7.5) | 4.5 (3.3–5.7) | 3.9 (2.7–5.2) | 1.7 (0.9–2.6)
Pennsylvania | 4.1 (3.5–4.8) | —^b^ | 5.5 (4.1–6.9) | 5.0 (3.8–6.3) | 1.5 (0.8–2.3)
Rhode Island | 0.8 (0.5–1.1) | —^b^ | —^b^ | 0.8 (0.3–1.3) | —^b^
South Carolina | 3.8 (2.9–4.6) | —^b^ | 4.4 (2.6–6.2) | 4.0 (2.6–5.3) | 2.1 (1.2–3.0)
South Dakota | 5.6 (4.3–6.9) | —^b^ | 6.5 (4.1–8.9) | 6.2 (4.1–8.3) | 2.1 (1.1–3.0)
Tennessee | 6.6 (5.5–7.7) | 10.2 (5.1–15.3) | 7.9 (5.8–10.0) | 5.2 (3.8–6.7) | 4.7 (2.9–6.5)
Texas | 3.3 (2.6–3.9) | 3.4 (1.6–5.2) | 3.3 (2.2–4.5) | 4.0 (2.7–5.3) | 1.8 (0.9–2.7)
Utah | 2.6 (2.2–3.0) | 2.3 (1.3–3.3) | 3.6 (2.8–4.4) | 2.3 (1.7–2.9) | 1.1 (0.6–1.6)
Vermont | 2.5 (1.9–3.1) | —^b^ | 4.5 (2.9–6.1) | 2.7 (1.6–3.9) | —^b^
Virginia | 3.4 (2.9–3.9) | 3.3 (1.7–5.0) | 4.4 (3.3–5.5) | 3.7 (2.8–4.6) | 1.5 (1.0–2.0)
Washington | 2.6 (2.2–3.0) | 2.1 (1.1–3.0) | 3.6 (2.8–4.4) | 2.8 (2.2–3.5) | 1.0 (0.5–1.4)
West Virginia | 8.5 (7.5–9.5) | 7.0 (2.9–11.1) | 11.5 (9.2–13.7) | 9.6 (8.0–11.1) | 4.5 (3.5–5.6)
Wisconsin | 3.8 (3.0–4.5) | —^b^ | 5.4 (3.8–6.9) | 3.3 (2.2–4.3) | 2.0 (1.0–3.0)
Wyoming | 8.9 (7.6–10.2) | 8.2 (3.7–12.6) | 13.2 (10.3–16.0) | 8.2 (6.3–10.1) | 4.2 (2.9–5.5)
Region
Northeast | 2.4 (2.2–2.6) | 2.7 (1.9–3.5) | 3.1 (2.7–3.5) | 2.6 (2.2–3.0) | 1.0 (0.7–1.3)
Midwest | 3.7 (3.5–3.9) | 3.5 (2.9–4.1) | 5.1 (4.7–5.6) | 3.7 (3.4–4.0) | 1.8 (1.6–2.0)
South | 3.9 (3.7–4.2) | 4.1 (3.4–4.8) | 4.5 (4.1–4.9) | 4.4 (4.0–4.8) | 2.4 (2.1–2.6)
West | 2.7 (2.4–2.9) | 3.6 (2.5–4.6) | 3.3 (2.8–3.8) | 2.6 (2.1–3.0) | 1.1 (0.8–1.4)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes: CI = confidence interval.

a Current use of smokeless tobacco products was defined as having ever used such products and using them every day or some days at the time of the survey.

b Estimate is not presented because of a relative standard error ≥30%. Relative standard error is equal to the standard error of a survey

Among young adults, data from 2020 on daily smokeless tobacco use were only available from five states while data on non-daily use were only available for 12 states due to unreliable estimates. In these states, daily use ranged from 0.9% (95% CI, 0.4–1.5) in Ohio to 6.1% (95% CI, 3.6–8.6) in Montana (Table 2.38), and non-daily use ranged from 1.4% (95% CI, 0.7–2.1) in Washington to 4.4% (95% CI, 2.3–6.5) in Montana (Table 2.39). Among young adults, daily use of smokeless tobacco was higher in the South (1.6%; 95% CI, 1.2–2.0) than it was in the Northeast (0.6%; 95% CI, 0.3–0.9) (Table 2.38); daily use of smokeless tobacco was otherwise similar by region. Non-Daily use of smokeless tobacco was similar across all four regions, ranging from 2.0% (95% CI, 1.5–2.5) in the West to 2.5% (95% CI, 1.9–3.1) in the South (Table 2.39).

##### Cigars

Youth. For the 36 states with available data, past-30-day use of cigars among U.S. high school students in 2019 ranged from 1.2% (95% CI, 0.6–2.2) in Utah to 11.7% (95% CI, 8.5–16.0) in Louisiana. The prevalence of past-30-day cigar use among youth was 2.7 percentage points (Connecticut, 3.9%; 95% CI, 3.0–4.9) to 10.5 percentage points (Louisiana, 11.7%; 95% CI, 8.5–16.0) higher in other states (with available data) than it was in Utah (Table 2.40).

Among states with available data, the prevalence of frequent cigar use (use on 20 or more days during the past 30 days) and daily cigar use was lowest in Utah (frequent use: 0.1%; 95% CI, 0.0–0.4; daily use: 0.1%; 95% CI, 0.0–0.4) and highest in Louisiana (frequent use: 2.1%; 95% CI, 1.1–4.1; daily use: 1.8%; 95% CI, 0.9–3.7). In most of the states with available data on cigar use, fewer than 1.0% of youth used cigars daily (Table 2.40).

Adults. State-level data on cigar smoking among adults are not available through the BRFSS.

Figure 2.18 Prevalence of current use of smokeless tobacco products^a^ a Current use of smokeless tobacco products was defined as having ever used such products and using them every day or some days at the time of the survey. among adults, 18 years of age and older, by region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Notes:CI = confidence interval.

In 2020, the prevalence of current use of smokeless tobacco among adults was highest in the South (3.9%) and Midwest (3.7%), followed by the West (2.7%) and the Northeast (2.4%).

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Table 2.38 Prevalence of daily use of smokeless tobacco products^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region % (95% CI) | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 3.2 (2.5–3.9) | —^b^ | 3.5 (2.2–4.8) | 4.0 (2.7–5.2) | 2.6 (1.5–3.8)
Alaska | 4.1 (3.3–5.0) | —^b^ | 4.2 (2.7–5.8) | 5.0 (3.4–6.7) | 4.3 (2.3–6.3)
Arizona | 1.3 (1.0–1.7) | —^b^ | 1.3 (0.7–1.9) | 2.1 (1.3–2.8) | —^b^
Arkansas | 3.8 (3.1–4.6) | —^b^ | 3.4 (2.1–4.7) | 5.9 (4.2–7.5) | 2.4 (1.6–3.3)
California | 0.9 (0.5–1.3) | —^b^ | —^b^ | —^b^ | —^b^
Colorado | 2.3 (1.9–2.7) | —^b^ | 2.8 (2.0–3.6) | 2.8 (2.1–3.5) | 0.9 (0.5–1.3)
Connecticut | 0.5 (0.3–0.7) | —^b^ | —^b^ | —^b^ | —^b^
Delaware | 1.1 (0.7–1.5) | —^b^ | —^b^ | —^b^ | —^b^
District of Columbia | 0.3 (0.1–0.6) | —^c^ | —^b^ | —^b^ | —^b^
Florida | 1.1 (0.8–1.4) | —^b^ | 0.7 (0.3–1.0) | 1.7 (1.1–2.3) | —^b^
Georgia | 2.1 (1.5–2.6) | —^b^ | 3.2 (1.9–4.5) | 1.5 (0.9–2.0) | 1.2 (0.8–1.6)
Hawai‘i | 0.7 (0.4–1.0) | —^b^ | —^b^ | 0.9 (0.5–1.4) | —^b^
Idaho | 3.0 (2.4–3.7) | —^b^ | 3.8 (2.4–5.1) | 4.1 (2.8–5.4) | 1.1 (0.6–1.7)
Illinois | 0.9 (0.5–1.2) | —^b^ | —^b^ | 1.1 (0.5–1.7) | —^b^
Indiana | 2.6 (2.1–3.0) | —^b^ | 3.6 (2.5–4.6) | 3.2 (2.4–3.9) | 1.3 (0.8–1.8)
Iowa | 2.7 (2.3–3.0) | 1.7 (0.7–2.6) | 3.8 (2.9–4.6) | 3.1 (2.5–3.8) | 1.2 (0.7–1.6)
Kansas | 3.3 (2.9–3.8) | —^b^ | 4.5 (3.6–5.5) | 4.1 (3.2–5.0) | 1.5 (0.9–2.1)
Kentucky | 4.1 (3.3–4.9) | —^b^ | 5.4 (3.6–7.1) | 4.1 (2.8–5.5) | 3.0 (1.7–4.3)
Louisiana | 3.5 (2.8–4.3) | —^b^ | 3.9 (2.5–5.2) | 4.5 (3.1–5.9) | 2.0 (1.0–3.0)
Maine | 1.5 (1.1–1.9) | —^b^ | 2.7 (1.6–3.9) | 1.6 (0.9–2.2) | —^b^
Maryland | 0.6 (0.5–0.8) | —^b^ | 0.6 (0.3–1.0) | 0.9 (0.5–1.2) | —^b^
Massachusetts | 0.5 (0.3–0.7) | —^b^ | —^b^ | —^b^ | —^c^
Michigan | 1.2 (0.9–1.6) | —^b^ | 1.8 (1.0–2.6) | 1.5 (0.9–2.1) | —^b^
Minnesota | 2.1 (1.8–2.3) | —^b^ | 2.9 (2.3–3.5) | 2.3 (1.9–2.8) | 1.1 (0.7–1.5)
Mississippi | 4.7 (3.9–5.4) | —^b^ | 5.3 (3.8–6.9) | 5.4 (4.2–6.7) | 4.2 (3.1–5.3)
Missouri | 2.9 (2.4–3.4) | —^b^ | 4.0 (3.0–5.0) | 3.2 (2.3–4.0) | 1.7 (1.0–2.3)
Montana | 5.3 (4.6–6.0) | 6.1 (3.6–8.6) | 6.8 (5.4–8.3) | 5.4 (4.2–6.5) | 3.1 (2.2–3.9)
Nebraska | 3.1 (2.7–3.5) | 1.4 (0.7–2.2) | 5.0 (3.9–6.0) | 3.4 (2.7–4.1) | 0.9 (0.6–1.2)
Nevada | 1.4 (0.9–2.0) | —^b^ | —^b^ | 2.2 (0.9–3.6) | —^b^
New Hampshire | 0.9 (0.5–1.3) | —^b^ | —^b^ | 1.0 (0.4–1.5) | —^b^
New Jersey | 0.6 (0.3–0.8) | —^b^ | —^b^ | 0.6 (0.3–0.8) | —^b^
New Mexico | 2.0 (1.6–2.5) | —^b^ | 2.0 (1.1–2.8) | 3.2 (2.1–4.2) | 1.1 (0.5–1.7)
New York | 1.0 (0.7–1.2) | —^b^ | 1.0 (0.6–1.4) | 1.6 (0.9–2.2) | —^b^
North Carolina | 2.1 (1.7–2.6) | —^b^ | 2.6 (1.6–3.5) | 2.6 (1.8–3.5) | 1.0 (0.4–1.5)
North Dakota | 3.9 (3.1–4.6) | —^b^ | 5.7 (3.9–7.5) | 4.1 (2.8–5.5) | 1.7 (1.0–2.4)
Ohio | 2.3 (2.0–2.7) | 0.9 (0.4–1.5) | 3.8 (2.9–4.7) | 2.3 (1.8–2.8) | 1.0 (0.6–1.5)
Oklahoma | 3.7 (3.0–4.4) | —^b^ | 3.5 (2.3–4.7) | 5.2 (3.9–6.4) | 2.9 (1.9–4.0)
Oregon | 2.2 (1.7–2.7) | —^b^ | 2.5 (1.6–3.4) | 2.8 (1.7–3.9) | —^b^
Pennsylvania | 2.4 (1.9–2.9) | —^b^ | 3.2 (2.1–4.3) | 3.1 (2.1–4.1) | —^b^
Rhode Island | 0.4 (0.2–0.6) | —^c^ | —^b^ | —^b^ | —^b^
South Carolina | 1.9 (1.3–2.6) | —^b^ | —^b^ | 2.0 (1.0–3.1) | 1.2 (0.5–1.9)
South Dakota | 3.7 (2.6–4.8) | —^b^ | 3.7 (1.9–5.5) | 4.5 (2.7–6.3) | —^b^
Tennessee | 3.8 (3.0–4.6) | 5.0 (2.4–7.6) | 5.0 (3.3–6.7) | 3.7 (2.4–4.9) | 1.7 (0.9–2.6)
Texas | 1.8 (1.3–2.3) | —^b^ | 2.0 (1.0–2.9) | 2.6 (1.7–3.6) | —^b^
Utah | 1.2 (1.0–1.5) | —^b^ | 1.6 (1.1–2.2) | 1.3 (0.8–1.8) | 0.6 (0.3–0.9)
Vermont | 1.6 (1.1–2.1) | —^b^ | 3.1 (1.7–4.4) | 1.9 (0.9–2.9) | —^b^
Virginia | 2.1 (1.6–2.5) | —^b^ | 2.4 (1.6–3.2) | 2.7 (1.9–3.5) | 0.8 (0.4–1.2)
Washington | 1.5 (1.2–1.8) | —^b^ | 2.1 (1.5–2.8) | 1.8 (1.3–2.2) | —^b^
West Virginia | 5.8 (4.9–6.6) | —^b^ | 7.5 (5.6–9.3) | 6.7 (5.3–8.0) | 3.3 (2.4–4.2)
Wisconsin | 2.1 (1.6–2.7) | —^b^ | 3.1 (1.9–4.4) | 2.1 (1.3–3.0) | —^b^
Wyoming | 5.5 (4.5–6.5) | —^b^ | 7.7 (5.4–10.0) | 6.5 (4.8–8.3) | 2.7 (1.7–3.8)
Region
Northeast | 1.2 (1.0–1.3) | 0.6 (0.3–0.9) | 1.4 (1.1–1.8) | 1.5 (1.2–1.8) | 0.5 (0.3–0.7)
Midwest | 2.0 (1.9–2.2) | 1.1 (0.8–1.5) | 2.9 (2.6–3.2) | 2.3 (2.1–2.5) | 1.0 (0.8–1.2)
South | 2.2 (2.1–2.4) | 1.6 (1.2–2.0) | 2.5 (2.2–2.8) | 2.7 (2.5–3.0) | 1.4 (1.1–1.6)
West | 1.4 (1.2–1.6) | 1.6 (0.7–2.4) | 1.5 (1.2–1.8) | 1.7 (1.4–2.1) | 0.7 (0.4–1.0)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes: CI = confidence interval.

a Daily use of smokeless tobacco products was defined as having ever used such products and using them every day at the time of the survey.

b Estimate is not presented because of a relative standard error ≥30%. Relative standard error is equal to the standard error of a survey estimate divided by the survey estimate and then multiplied by 100.

c Data were not available for this age group in this state.

Table 2.39 Prevalence of nondaily use of smokeless tobacco products^a^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region % (95% CI) | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 2.5 (1.9–3.1) | —^b^ | 3.2 (2.0–4.5) | 2.3 (1.4–3.3) | 1.3 (0.7–1.9)
Alaska | 3.1 (2.1–4.1) | —^b^ | 4.7 (2.4–6.9) | 1.6 (0.7–2.4) | —^b^
Arizona | 1.6 (1.3–2.0) | 3.4 (1.6–5.3) | 2.2 (1.5–3.0) | 1.1 (0.7–1.5) | 0.6 (0.2–0.9)
Arkansas | 3.0 (2.1–3.8) | —^b^ | 3.3 (1.9–4.7) | 1.9 (1.0–2.8) | 1.8 (1.0–2.5)
California | 0.9 (0.6–1.2) | —^b^ | 1.5 (0.8–2.2) | —^b^ | —^b^
Colorado | 1.3 (1.0–1.6) | 2.4 (1.2–3.6) | 1.9 (1.3–2.5) | 0.7 (0.4–1.0) | 0.6 (0.3–0.9)
Connecticut | 1.2 (0.8–1.6) | —^b^ | 1.6 (0.8–2.3) | 0.9 (0.4–1.4) | —^b^
Delaware | 1.3 (0.6–2.0) | —^b^ | —^b^ | —^b^ | —^b^
District of Columbia | 1.5 (0.8–2.2) | —^b^ | —^b^ | —^b^ | —^b^
Florida | 1.2 (0.8–1.6) | —^b^ | 1.2 (0.6–1.8) | 2.0 (0.9–3.1) | —^b^
Georgia | 1.5 (1.2–1.9) | 2.3 (1.0–3.6) | 1.3 (0.7–2.0) | 1.5 (0.9–2.1) | 1.6 (1.0–2.2)
Hawai‘i | 1.6 (1.1–2.0) | —^b^ | 2.2 (1.4–3.0) | 1.2 (0.6–1.8) | 0.8 (0.3–1.3)
Idaho | 2.1 (1.6–2.7) | 3.6 (1.5–5.7) | 3.2 (1.9–4.4) | —^b^ | —^b^
Illinois | 1.0 (0.5–1.4) | —^b^ | —^b^ | —^b^ | —^b^
Indiana | 2.0 (1.5–2.4) | —^b^ | 2.7 (1.8–3.7) | 1.4 (0.9–1.9) | 1.2 (0.7–1.7)
Iowa | 1.7 (1.4–2.1) | 3.8 (2.0–5.6) | 1.9 (1.3–2.5) | 1.5 (1.0–1.9) | 0.7 (0.3–1.1)
Kansas | 1.9 (1.5–2.2) | 2.8 (1.4–4.3) | 2.4 (1.7–3.1) | 1.5 (1.0–1.9) | 1.0 (0.5–1.5)
Kentucky | 2.0 (1.4–2.7) | —^b^ | 3.0 (1.5–4.5) | 2.0 (1.1–2.8) | —^b^
Louisiana | 2.0 (1.4–2.6) | —^b^ | 2.5 (1.3–3.7) | 1.6 (0.9–2.3) | —^b^
Maine | 1.2 (0.8–1.7) | —^b^ | 2.1 (1.2–3.1) | —^b^ | 0.7 (0.3–1.1)
Maryland | 1.1 (0.8–1.4) | —^b^ | 1.6 (0.9–2.2) | —^b^ | —^b^
Massachusetts | 1.1 (0.7–1.5) | —^b^ | —^b^ | 0.7 (0.4–1.1) | —^b^
Michigan | 1.6 (1.2–2.1) | —^b^ | 2.8 (1.8–3.8) | 1.1 (0.5–1.6) | —^b^
Minnesota | 1.7 (1.4–1.9) | 3.5 (2.3–4.7) | 2.0 (1.5–2.5) | 1.4 (1.1–1.8) | 0.5 (0.3–0.8)
Mississippi | 2.4 (1.9–3.0) | —^b^ | 2.6 (1.7–3.6) | 2.7 (1.8–3.5) | 1.6 (1.0–2.2)
Missouri | 2.0 (1.6–2.4) | —^b^ | 2.8 (1.9–3.6) | 2.1 (1.4–2.8) | 0.6 (0.2–0.9)
Montana | 2.7 (2.2–3.2) | 4.4 (2.3–6.5) | 3.9 (2.7–5.0) | 2.3 (1.5–3.1) | 0.8 (0.4–1.1)
Nebraska | 2.0 (1.7–2.4) | 3.3 (2.1–4.5) | 2.7 (1.9–3.6) | 1.6 (1.1–2.2) | 0.7 (0.4–1.1)
Nevada | 1.6 (1.0–2.2) | —^b^ | —^b^ | —^b^ | —^b^
New Hampshire | 0.9 (0.6–1.3) | —^b^ | —^b^ | —^b^ | —^b^
New Jersey | 1.0 (0.7–1.2) | —^b^ | 1.3 (0.8–1.8) | 0.7 (0.4–1.0) | —^b^
New Mexico | 1.6 (1.1–2.1) | —^b^ | 2.6 (1.4–3.9) | —^b^ | —^b^
New York | 1.2 (0.9–1.4) | —^b^ | 1.6 (1.1–2.1) | 0.9 (0.5–1.3) | —^b^
North Carolina | 1.8 (1.3–2.2) | —^b^ | 2.2 (1.3–3.1) | 1.7 (0.8–2.5) | 1.3 (0.6–2.1)
North Dakota | 2.5 (1.8–3.2) | —^b^ | 3.0 (1.7–4.2) | 2.1 (1.1–3.2) | 0.7 (0.3–1.1)
Ohio | 1.8 (1.5–2.2) | 2.4 (1.1–3.7) | 2.4 (1.7–3.0) | 1.8 (1.3–2.3) | 0.9 (0.5–1.3)
Oklahoma | 3.4 (2.6–4.1) | —^b^ | 5.0 (3.4–6.7) | 2.3 (1.4–3.1) | 2.0 (1.2–2.8)
Oregon | 1.6 (1.1–2.0) | —^b^ | 2.0 (1.2–2.8) | 1.1 (0.6–1.7) | —^b^
Pennsylvania | 1.8 (1.3–2.2) | —^b^ | 2.3 (1.4–3.2) | 1.9 (1.1–2.7) | —^b^
Rhode Island | 0.4 (0.2–0.6) | —^b^ | —^b^ | —^b^ | —^b^
South Carolina | 1.8 (1.3–2.4) | —^b^ | 2.4 (1.1–3.7) | 2.0 (1.1–2.9) | —^b^
South Dakota | 1.9 (1.2–2.6) | —^b^ | —^b^ | —^b^ | —^b^
Tennessee | 2.7 (1.9–3.6) | —^b^ | 2.9 (1.5–4.2) | 1.6 (0.8–2.3) | 3.0 (1.4–4.6)
Texas | 1.5 (1.0–1.9) | —^b^ | 1.4 (0.8–2.0) | —^b^ | —^b^
Utah | 1.4 (1.1–1.7) | 1.5 (0.7–2.3) | 1.9 (1.3–2.6) | 1.0 (0.5–1.4) | —^b^
Vermont | 0.9 (0.6–1.2) | —^b^ | 1.4 (0.6–2.2) | —^b^ | —^b^
Virginia | 1.3 (1.0–1.6) | —^b^ | 2.0 (1.3–2.7) | 1.0 (0.6–1.4) | 0.6 (0.3–1.0)
Washington | 1.1 (0.9–1.3) | 1.4 (0.7–2.1) | 1.4 (0.9–1.9) | 1.1 (0.7–1.5) | —^b^
West Virginia | 2.7 (2.1–3.3) | —^b^ | 4.0 (2.5–5.4) | 2.9 (2.0–3.7) | 1.2 (0.7–1.7)
Wisconsin | 1.6 (1.2–2.1) | —^b^ | 2.3 (1.3–3.2) | —^b^ | —^b^
Wyoming | 3.4 (2.5–4.3) | —^b^ | 5.5 (3.6–7.4) | 1.7 (0.8–2.5) | 1.5 (0.7–2.2)
Region
Northeast | 1.2 (1.1–1.4) | 2.1 (1.3–2.8) | 1.7 (1.3–2.0) | 1.1 (0.8–1.3) | 0.5 (0.3–0.7)
Midwest | 1.6 (1.5–1.8) | 2.3 (1.8–2.8) | 2.3 (2.0–2.6) | 1.4 (1.2–1.6) | 0.8 (0.6–0.9)
South | 1.7 (1.6–1.9) | 2.5 (1.9–3.1) | 2.0 (1.7–2.2) | 1.6 (1.3–1.9) | 1.0 (0.8–1.2)
West | 1.2 (1.1–1.4) | 2.0 (1.5–2.5) | 1.8 (1.4–2.2) | 0.8 (0.6–1.1) | 0.4 (0.3–0.5)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes: CI = confidence interval.

a Nondaily use of smokeless tobacco products was defined having ever used such products and using them some days at the time of the survey.

b Estimate is not presented because of a relative standard error ≥30%. Relative standard error is equal to the standard error of a survey estimate divided by the survey estimate and then multiplied by 100.

Table 2.40 Prevalence of cigar use^a^ among high school students, by location; national Youth Risk Behavior Survey (YRBS) 2019, United States

Location | Past-30-day use:^b^ % (95% CI) | ≥20-days use:^c^ % (95% CI) | Daily use:^d^ % (95% CI)
Alabama | 9.5 (7.1–12.6) | 1.7 (1.1–2.5) | 1.1 (0.7–1.8)
Alaska | 4.6 (3.5–6.0) | 0.4 (0.2–0.9) | 0.2 (0.1–0.4)
Arizona | 4.9 (3.5–6.8) | 0.5 (0.2–1.1) | 0.4 (0.2–0.8)
Arkansas | 8.4 (6.8–10.4) | 0.9 (0.4–1.8) | 0.6 (0.3–1.4)
California | —^e^ | —^e^ | —^e^
Colorado | —^e^ | —^e^ | —^e^
Connecticut | 3.9 (3.0–4.9) | 0.9 (0.6–1.6) | 0.8 (0.4–1.7)
Delaware | —^e^ | —^e^ | —^e^
District of Columbia | —^e^ | —^e^ | —^e^
Florida | —^e^ | —^e^ | —^e^
Georgia | 5.4 (4.1–7.1) | 0.8 (0.5–1.1) | 0.6 (0.4–0.8)
Hawai‘i | —^e^ | —^e^ | —^e^
Idaho | 4.1 (3.0–5.5) | 0.2 (0.0–0.9) | 0.0 (0.0–0.3)
Illinois | 6.1 (4.7–7.8) | 0.9 (0.5–1.7) | 0.6 (0.3–1.2)
Indiana | —^e^ | —^e^ | —^e^
Iowa | 4.4 (3.5–5.4) | 0.6 (0.3–1.2) | 0.5 (0.2–1.3)
Kansas | 5.5 (4.1–7.3) | 0.8 (0.4–1.3) | 0.6 (0.3–1.2)
Kentucky | 7.9 (6.2–10.0) | 1.6 (1.0–2.6) | 1.5 (0.9–2.4)
Louisiana | 11.7 (8.5–16.0) | 2.1 (1.1–4.1) | 1.8 (0.9–3.7)
Maine | 5.0 (4.4–5.7) | 0.7 (0.6–0.9) | 0.5 (0.4–0.6)
Maryland | 6.0 (5.5–6.6) | 0.9 (0.8–1.0) | 0.6 (0.5–0.8)
Massachusetts | 5.1 (3.7–6.8) | 0.7 (0.3–1.3) | 0.6 (0.3–1.2)
Michigan | 5.2 (3.9–6.9) | 0.6 (0.3–1.1) | 0.3 (0.1–0.6)
Minnesota | —^e^ | —^e^ | —^e^
Mississippi | 9.1 (7.7–10.6) | 1.5 (0.9–2.5) | 1.0 (0.5–1.9)
Missouri | 5.4 (4.3–6.9) | 0.4 (0.1–1.2) | 0.4 (0.1–1.2)
Montana | 7.5 (6.4–8.8) | 0.6 (0.4–1.0) | 0.5 (0.3–0.9)
Nebraska | 4.1 (2.9–5.7) | 0.9 (0.4–1.7) | 0.6 (0.2–1.5)
Nevada | —^e^ | —^e^ | —^e^
New Hampshire | —^e^ | —^e^ | —^e^
New Jersey | —^e^ | —^e^ | —^e^
New Mexico | 8.3 (7.1–9.7) | 1.3 (1.0–1.7) | 0.8 (0.6–1.2)
New York | 6.7 (5.8–7.7) | 0.8 (0.6–1.2) | 0.6 (0.4–0.9)
North Carolina | —^e^ | —^e^ | —^e^
North Dakota | 5.2 (3.9–7.0) | 1.0 (0.5–1.7) | 0.6 (0.3–1.3)
Ohio | 7.2 (6.3–8.2) | 0.5 (0.2–1.0) | 0.4 (0.2–0.9)
Oklahoma | 6.8 (5.1–8.9) | 1.0 (0.5–1.9) | 0.8 (0.4–1.6)
Oregon | —^e^ | —^e^ | —^e^
Pennsylvania | 5.9 (4.7–7.3) | 0.9 (0.5–1.7) | 0.5 (0.2–1.1)
Rhode Island | 5.1 (3.7–6.9) | 0.7 (0.4–1.5) | 0.7 (0.3–1.5)
South Carolina | 9.1 (6.8–12.1) | 1.8 (1.0–3.1) | 1.6 (0.9–3.0)
South Dakota | 7.1 (4.6–10.7) | 0.8 (0.3–1.9) | 0.4 (0.1–1.0)
Tennessee | 9.1 (6.4–12.7) | 1.4 (0.8–2.2) | 0.9 (0.5–1.6)
Texas | 5.7 (4.5–7.2) | 0.9 (0.6–1.5) | 0.5 (0.2–1.3)
Utah | 1.2 (0.6–2.2) | 0.1 (0.0–0.4) | 0.1 (0.0–0.4)
Vermont | 5.8 (5.5–6.2) | 0.9 (0.8–1.1) | 0.8 (0.6–0.9)
Virginia | 4.7 (4.0–5.5) | 1.2 (0.8–1.8) | 0.9 (0.6–1.5)
Washington | —^e^ | —^e^ | —^e^
West Virginia | 10.9 (8.7–13.4) | 1.3 (0.9–2.1) | 1.1 (0.8–1.7)
Wisconsin | 4.7 (3.3–6.6) | 0.5 (0.3–0.8) | 0.3 (0.2–0.6)
Wyoming | —^e^ | —^e^ | —^e^

Source: CDC (n.d.a).

Notes: CI = confidence interval.

a Includes use of cigars, cigarillos, or little cigars.

b On at least 1 day during the 30 days before the survey.

c On 20 or more days during the 30 days before the survey.

d On all 30 days during the 30 days before the survey.

e The number of respondents within the subgroup did not meet the minimum reporting threshold or data were not available.

### Patterns of Polytobacco Use

Current polytobacco product use was defined in the BRFSS as concurrent use of at least two out of three tobacco products—cigarettes, smokeless tobacco, and e-cigarettes. Among states with available data, current polytobacco product use among adults in 2020 ranged from 0.7% (95% CI, 0.4–1.0) in Massachusetts to 4.4% in Alaska (95% CI, 3.3–5.6), West Virginia (95% CI, 3.6–5.2), and Wyoming (95% CI, 3.4–5.4) (Table 2.41). The prevalence of current polytobacco product use among adults was 0.8 percentage points (New York, 1.5%; 95% CI, 1.2–1.8) to 3.7 percentage points (Alaska, West Virginia, and Wyoming, 4.4%) higher in other states (with available data) than it was in Massachusetts. By region, use of multiple tobacco products was higher in the South (2.5%; 95% CI, 2.3–2.7) and the Midwest (2.3%; 95% CI, 2.1–2.5) than it was in the Northeast (1.8%; 95% CI, 1.6–2.0) and the West (1.4%; 95% CI, 1.2–1.5).

Among young adults in 2020, many estimates of polytobacco product use were suppressed because of data instability. The remaining estimates from 26 states in 2020 ranged from 2.3% (95% CI, 1.0–3.6) in Maryland to 9.6% (95% CI, 6.4–12.9) in Montana (Table 2.41). The prevalence of current polytobacco product use among young adults was 0.7 percentage points (Florida, 3.0%; 95% CI, 1.3–4.7) to 7.3 percentage points (Montana, 9.6%; 95% CI, 6.4–12.9) higher in other states (with available data) than it was in Maryland. By region, polytobacco use ranged from 2.6% (95% CI, 1.7–3.4) in the West to 4.4% (95% CI, 3.6–5.2) in the South.

### Urban and Rural Differences in Tobacco Use

Previous studies have documented the higher prevalence of cigarette and smokeless tobacco use in rural versus urban areas of the United States (Roberts et al. 2016b, 2017; Doogan et al. 2017; Cepeda-Benito et al. 2018; Talbot et al. 2019). The higher prevalence of tobacco use in rural populations is not equally distributed across the nation, nor is it consistent across tobacco products (Roberts et al. 2016b).

#### Patterns of Ever and Current Use of Cigarettes

##### Youth

Among youth, the location of their school in an urban or rural county is associated with trends in tobacco use over time. For example, examining data from the NYTS for 2011–2014, Pesko and Robarts (2017) found that the odds of past-30-day use of cigarettes (OR = 1.27; 95% CI, 1.08–1.51) was significantly higher, after adjusting for covariates, among rural youth than it was for urban youth. However, during the 3-year period, cigarette use decreased among rural (from 17.5% in 2011 to 6.5% in 2014) and urban youth (from 8.1% in 2011 to 4.9% in 2014) (Pesko and Robarts 2017).

Table 2.41 Prevalence of current use^a^ of multiple tobacco products^b^ among adults, 18 years of age and older, by age group and location and region; Behavioral Risk Factor Surveillance System (BRFSS) 2020, United States

Location and region | Overall: % (95% CI) | 18–24 years of age: % (95% CI) | 25–44 years of age: % (95% CI) | 45–64 years of age: % (95% CI) | ≥65 years of age: % (95% CI)
Location
Alabama | 2.8 (2.2–3.5) | 5.8 (2.8–8.7) | 4.0 (2.7–5.3) | 2.3 (1.4–3.3) | —^c^
Alaska | 4.4 (3.3–5.6) | 8.6 (3.7–13.6) | 6.3 (4.0–8.6) | 2.8 (1.4–4.1) | —^c^
Arizona | —^d^ | —^d^ | —^d^ | —^d^ | —^d^
Arkansas | 4.3 (3.4–5.2) | 9.0 (4.2–13.7) | 5.9 (4.1–7.7) | 3.3 (2.2–4.4) | 1.0 (0.5–1.5)
California | —^d^ | —^d^ | —^d^ | —^d^ | —^d^
Colorado | —^d^ | —^d^ | —^d^ | —^d^ | —^d^
Connecticut | 1.8 (1.4–2.2) | 3.2 (1.4–5.0) | 3.2 (2.2–4.1) | 1.2 (0.6–1.7) | —^c^
Delaware | 2.1 (1.4–2.7) | —^c^ | 3.5 (1.8–5.1) | 1.3 (0.7–1.9) | —^c^
District of Columbia | —^d^ | —^d^ | —^d^ | —^d^ | —^d^
Florida | 1.8 (1.4–2.3) | 3.0 (1.3–4.7) | 2.5 (1.7–3.4) | 2.0 (1.0–3.0) | —^c^
Georgia | 3.1 (2.4–3.7) | 6.3 (3.3–9.2) | 4.5 (3.3–5.8) | 1.7 (1.1–2.4) | —^c^
Hawai‘i | 2.1 (1.7–2.6) | 6.5 (3.6–9.3) | 3.0 (2.1–4.0) | 1.0 (0.5–1.5) | —^c^
Idaho | 3.0 (2.4–3.7) | 6.1 (3.3–8.9) | 4.9 (3.5–6.3) | 1.5 (0.7–2.3) | —^c^
Illinois | 1.6 (1.1–2.1) | —^c^ | 1.9 (1.0–2.8) | 1.3 (0.6–2.1) | —^c^
Indiana | 3.6 (3.0–4.2) | 4.6 (2.5–6.8) | 5.6 (4.3–6.9) | 2.9 (2.2–3.6) | 1.1 (0.6–1.6)
Iowa | —^d^ | —^d^ | —^d^ | —^d^ | —^d^
Kansas | 2.5 (2.1–3.0) | 4.1 (2.2–6.0) | 3.7 (2.7–4.6) | 2.1 (1.4–2.8) | —^c^
Kentucky | 4.0 (3.2–4.9) | —^c^ | 7.3 (5.2–9.3) | 3.2 (2.1–4.2) | —^c^
Louisiana | —^d^ | —^d^ | —^d^ | —^d^ | —^d^
Maine | 2.3 (1.7–2.9) | —^c^ | 4.5 (3.2–5.9) | 1.0 (0.5–1.4) | 0.7 (0.3–1.1)
Maryland | 1.7 (1.3–2.1) | 2.3 (1.0–3.6) | 2.7 (1.8–3.6) | 1.5 (0.9–2.2) | —^c^
Massachusetts | 0.7 (0.4–1.0) | —^c^ | 1.2 (0.5–1.8) | 0.4 (0.1–0.7)c | —^c^
Michigan | 1.9 (1.5–2.4) | 3.0 (1.5–4.5) | 3.4 (2.3–4.5) | 1.3 (0.8–1.8) | —^c^
Minnesota | 2.5 (2.1–2.8) | 5.2 (3.6–6.9) | 3.7 (3.0–4.4) | 1.6 (1.3–2.0) | 0.4 (0.2–0.6)
Mississippi | 2.8 (2.2–3.3) | —^c^ | 4.5 (3.2–5.7) | 2.4 (1.6–3.3) | 0.7 (0.3–1.2)
Missouri | 2.9 (2.4–3.4) | 4.6 (2.7–6.6) | 4.6 (3.5–5.8) | 2.3 (1.6–3.0) | —^c^
Montana | 3.5 (2.9–4.2) | 9.6 (6.4–12.9) | 5.6 (4.1–7.0) | 1.3 (0.8–1.8) | 0.9 (0.5–1.4)
Nebraska | 2.9 (2.4–3.3) | 5.9 (4.0–7.8) | 4.1 (3.2–5.0) | 1.9 (1.3–2.5) | 0.6 (0.3–0.8)
Nevada | 2.0 (1.4–2.7) | —^c^ | 3.2 (1.8–4.6) | —^c^ | —^c^
New Hampshire | 2.4 (1.8–3.0) | —^c^ | 4.3 (2.8–5.9) | 1.3 (0.7–1.9) | —^c^
New Jersey | 1.8 (1.4–2.2) | 3.1 (1.7–4.5) | 3.0 (2.1–3.9) | 1.2 (0.7–1.7) | —^c^
New Mexico | 2.7 (2.0–3.5) | —^c^ | 5.0 (3.1–7.0) | 1.7 (0.7–2.6) | —^c^
New York | 1.5 (1.2–1.8) | —^c^ | 1.9 (1.4–2.5) | 2.1 (1.4–2.7) | 0.4 (0.2–0.7)
North Carolina | 2.8 (2.3–3.3) | 3.6 (1.6–5.6) | 3.2 (2.3–4.1) | 3.0 (2.1–4.0) | 1.4 (0.6–2.2)
North Dakota | 3.8 (2.9–4.7) | 6.0 (2.7–9.3) | 6.0 (4.2–7.9) | 2.6 (1.5–3.7) | —^c^
Ohio | 3.1 (2.6–3.5) | 5.3 (3.5–7.1) | 4.7 (3.7–5.6) | 2.3 (1.8–2.8) | 0.8 (0.4–1.1)
Oklahoma | —^d^ | —^d^ | —^d^ | —^d^ | —^d^
Oregon | 2.4 (1.8–2.9) | 5.4 (2.7–8.1) | 3.7 (2.6–4.7) | 1.3 (0.7–1.8) | —^c^
Pennsylvania | 2.7 (2.1–3.3) | —^c^ | 4.3 (2.9–5.7) | 2.1 (1.4–2.9) | —^c^
Rhode Island | 2.2 (1.5–2.9) | —^c^ | 3.1 (1.7–4.4) | 1.4 (0.7–2.0) | —^c^
South Carolina | —^d^ | —^d^ | —^d^ | —^d^ | —^d^
South Dakota | 2.1 (1.4–2.9) | —^c^ | 4.4 (2.3–6.5) | —^c^ | —^c^
Tennessee | 3.8 (2.8–4.8) | —^c^ | 4.5 (3.1–5.9) | 2.7 (1.7–3.6) | —^c^
Texas | 2.5 (2.0–3.1) | 4.5 (2.4–6.6) | 2.7 (1.7–3.7) | 2.7 (1.7–3.7) | —^c^
Utah | 2.7 (2.2–3.1) | 4.1 (2.7–5.5) | 3.6 (2.7–4.5) | 1.9 (1.3–2.4) | —^c^
Vermont | 2.0 (1.2–2.7) | —^c^ | 3.1 (1.8–4.4) | 1.0 (0.6–1.5) | —^c^
Virginia | 2.4 (1.9–2.9) | 3.9 (2.1–5.6) | 3.9 (2.8–5.1) | 1.7 (1.1–2.3) | —^c^
Washington | 2.4 (2.1–2.8) | 3.4 (2.0–4.7) | 3.8 (3.0–4.7) | 1.6 (1.2–2.1) | 0.9 (0.4–1.3)
West Virginia | 4.4 (3.6–5.2) | —^c^ | 8.4 (6.5–10.3) | 3.3 (2.4–4.2) | 0.7 (0.3–1.1)
Wisconsin | —^d^ | —^d^ | —^d^ | —^d^ | —^d^
Wyoming | 4.4 (3.4–5.4) | 7.9 (3.8–12.0) | 6.9 (4.8–9.1) | 2.8 (1.7–4.0) | —^c^
Region
Northeast | 1.8 (1.6–2.0) | 2.7 (1.9–3.5) | 2.8 (2.3–3.2) | 1.6 (1.3–1.9) | 0.4 (0.2–0.5)
Midwest | 2.3 (2.1–2.5) | 3.8 (3.2–4.4) | 3.5 (3.2–3.8) | 1.8 (1.5–2.0) | 0.6 (0.4–0.7)
South | 2.5 (2.3–2.7) | 4.4 (3.6–5.2) | 3.3 (3.0–3.7) | 2.3 (2.0–2.6) | 0.6 (0.5–0.7)
West | 1.4 (1.2–1.5) | 2.6 (1.7–3.4) | 2.0 (1.6–2.3) | 0.9 (0.6–1.1) | 0.3 (0.2–0.5)

Source: BRFSS, Centers for Disease Control and Prevention, public use data, 2020.

Notes: CI = confidence interval.

a Current use of cigarettes was defined as having smoked 100 cigarettes in a lifetime and smoking every day or some days at the time of the survey. Current use of other tobacco products (smokeless tobacco, e-cigarettes) was defined as having ever used such products and using them every day or some days at the time of the survey.

b Includes current use of two or more tobacco products. Data were excluded from adults whose current use status was missing across all three products (i.e., cigarettes, smokeless tobacco, and e-cigarettes).

c Estimate is not presented because of a relative standard error >30%.

d Eight states (Arizona, California, Colorado, Iowa, Louisiana, Oklahoma, South Carolina, and Wisconsin) and the District of Columbia did not field the 2020 BRFSS optional module for e-cigarettes.

Trend data in other studies show that disparities in tobacco use have remained or widened over time between youth who live in rural areas and those who live in urban areas. One study, using NSDUH data from 2008 to 2016, estimated that the prevalence of smoking did not differ between rural youth and urban youth in 2008–2010, but rural youth had 54% higher odds of past-month cigarette smoking than did urban youth in 2014–2016 (Ziller et al. 2019). Using 20 years of data from the Monitoring the Future Study, another study showed that (a) disparities in ever cigarette use, ever regular cigarette smoking, and current regular cigarette smoking persisted from 1998 to 2018, and (b) the difference in ever cigarette use between rural and urban youth widened from 6.9 percentage points in 1998 to 13.5 percentage points in 2018 (rural: 34.4% vs. urban: 20.9% in 2018) (Kim and Selya 2021).

##### Adults

The literature generally suggests that the prevalence of smoking cigarettes is higher in rural areas than it is in urban areas (Vander Weg et al. 2011; Doogan et al. 2017; Nighbor et al. 2018; Coughlin et al. 2019; Parker et al. 2022). According to the 2008 BRFSS, the odds of lifetime smoking (having smoked at least 100 cigarettes in one’s lifetime) were lower among adults living in suburban and urban areas (suburban: aOR = 0.95; 95% CI, 0.92–0.98; urban: aOR = 0.95; 95% CI, 0.92–0.99) and the odds of current smoking (having smoked every day or some days at the time of the survey) were lower among adults living in suburban and urban areas (suburban: aOR = 0.87; 95% CI, 0.83–0.91; urban: aOR = 0.90; 95% CI, 0.86–0.95) than they were among adults living in rural areas (Vander Weg et al. 2011).

Similarly, a study using 2007–2014 data from the NSDUH showed that in 2007, the odds of current smoking (having smoked at least 100 cigarettes in the lifetime and at least one cigarette during the past 30 days) were higher among adults living in rural areas (OR = 1.30; 95% CI, 1.22–1.38) than they were among adults living in urban areas, but the relationship was not significant after adjusting for age, gender, race, education, income, unemployment, outdoor occupation, marital status, anxiety, depression, health insurance status, smokeless tobacco use, and substance use (Doogan et al. 2017). However, an interaction between time (integer coded from zero [year 2007] to seven [year 2014]) and rural status indicated that the time slope for rural residents differed from that of urban residents. Specifically, the time coefficient suggested there was a 3% decrease in the odds of smoking among urban residents for each year from 2007 to 2014 (OR = 0.97; 95% CI, 0.96–0.98), but the rural trend was not significant in post hoc interaction analyses (OR = 0.99; 95% CI, 0.98–1.00). Furthermore, the adjusted odds of smoking in 2014 were significantly higher among rural residents (aOR = 1.19; 95% CI, 1.11–1.27) than they were among urban residents (Doogan et al. 2017).

Using more recent data from the 2007–2017 NSDUH, Coughlin and colleagues (2019) reported that the urban–rural disparity in current use of cigarettes increased during this period because the prevalence of current cigarette use declined more rapidly in urban areas than it did in rural areas during this period. The odds of cigarette use among people living in urban areas was 15% lower in 2017 (aOR = 0.85; 95% CI: 0.81–0.88) than it was in 2007, and the odds of cigarette use among people living in rural areas was 8% lower in 2017 (aOR = 0.92; 95% CI, 0.85–0.99) than it was in 2007 (Coughlin et al. 2019). Finally, the 2013–2014 wave of the PATH Study revealed that both past-30-day and daily cigarette use were higher among residents of rural areas (past-30-day use: 24.6%; daily use: 18.3%) than they were among residents of urban areas (past-30-day use: 22.0%; daily use: 13.4%) (Roberts et al. 2017).

Patterns of smoking in urban and rural areas vary by region of the United States. According to pooled data from the 2012–2013 NSDUH, differences in urban and rural smoking patterns were not significant in the West and the Midwest. In the Northeast (specifically, in the New England division) and in the South, however, daily smoking was higher among people in rural areas compared with those in urban areas; in the South, the rate of any past-30-day smoking was also higher among people in rural areas than it was among those in urban areas (Roberts et al. 2016b). Notably, in both the West and Midwest, past-30-day use of menthol cigarettes was lower in rural areas than it was in urban areas (Roberts et al. 2016b).

#### Cigarette Use by Urban and Rural Residence and Sex

Some differences are known to exist in patterns of urban and rural smoking by sex. Rural men, according to the combined 2007–2014 NSDUH, had the highest prevalence of current (30.1%) and daily (21.8%) smoking, followed by rural women (current: 24.8%; daily: 18.9%), urban men (current: 23.9%; daily: 15.0%), and urban women (current: 18.8%; daily: 12.8%) (Cepeda-Benito et al. 2018). Over time, the prevalence of smoking declined among rural men, urban men, and urban women but was flat among rural women; the prevalence of smoking among rural women surpassed that of urban men in 2014 (Cepeda-Benito et al. 2018).

Nighbor and colleagues (2018) analyzed data from the 2007–2016 NSDUH survey to estimate current cigarette use among women of reproductive age (15–44 years of age), including those who were pregnant. Although current cigarette use declined among women overall from 2007 to 2016, the prevalence of cigarette use remained higher among rural women of reproductive age than it was among urban women of reproductive age. The prevalence of cigarette smoking did not decline significantly from 2007 to 2016 among both rural and urban women who were pregnant, but the prevalence of cigarette use was higher among rural women who were pregnant than it was among urban women who were pregnant across this period. However, a statistically significant interaction was observed between residency and pregnancy status: the odds of cigarette smoking were 25% (aOR = 0.75; 95% CI, 0.62–0.92) lower among rural women who were pregnant than they were among rural women who were not pregnant, and the odds of cigarette smoking were 42% (aOR = 0.58; 95% CI, 0.53–0.63) lower among urban women who were pregnant than they were among urban women who were not pregnant, suggesting greater pregnancy-related quitting among urban women (Nighbor et al. 2018).

#### Patterns of the Use of Other Tobacco Products

Examining pooled data from the NYTS for 2011–2014, Pesko and Robarts (2017) found that, compared with youth living in urban areas, youth living in rural areas had a higher prevalence of smokeless tobacco use (7.0% vs. 2.9%, p <0.001), multiple tobacco product use (10.3% vs. 7.3%, p <0.001), and use of any tobacco product (17.0% vs. 13.1%, p = 0.006). However, after adjusting for covariates, only the odds of past-30-day use of smokeless tobacco (OR = 1.51; 95% CI, 1.24–1.83) was significantly higher among rural youth than it was among urban youth. During this 3-year period, cigar and smokeless tobacco use decreased among rural and urban youth. Use of multiple tobacco products increased among urban youth (from 6.9% to 8.9%, p = 0.02), but it declined among rural youth (from 14.5% to 8.3%, p = 0.002). Use of any tobacco product also declined among rural youth but did not change significantly over time among urban youth. While use of e-cigarettes increased among rural and urban youth, this study found that past-30-day use of e-cigarettes grew at a greater rate over this period for urban youth (from 0.9% in 2011 to 8.6% in 2014) compared with rural youth (2.1% in 2011 to 4.3% in 2014) (Pesko and Robarts 2017).

In another study examining data from the NYTS for 2011–2016, Wiggins and colleagues (2020) found no differences in the rate of change in any tobacco product use prevalence measure over time between rural and urban middle or high school students. Furthermore, Noland and colleagues (2018), in their study of NYTS data among youth who in 2014 had smoked conventional cigarettes during the past 30 days, found that those attending an urban school were 86% more likely than their counterparts in rural schools to have also used e-cigarettes during the past 30 days, but among youth who did not smoke, the likelihood of using e-cigarettes did not differ between youth in urban schools and those attending rural schools.

Similar to cigarette smoking, use of smokeless tobacco tends to be higher among people living in rural areas than among those living in urban areas. BRFSS data from 2008 revealed that the odds of ever trying smokeless tobacco were lower among adults living in suburban (aOR = 0.72; 95% CI, 0.64–0.80) and urban (aOR = 0.59; 95% CI, 0.52–0.66) areas than they were among adults living in rural areas; this was also true for current use (every day or some days) of smokeless tobacco (Vander Weg et al. 2011). Data from the NSDUH further show this relationship. Among individuals 12 years of age and older, a higher prevalence of smokeless tobacco use was observed in rural areas compared with urban areas across all four regions of the United States and in almost all nine statistical divisions in the United States (Roberts et al. 2016b). According to the PATH Study, past-30-day use of smokeless tobacco was three times more prevalent among adults in rural areas than it was in urban areas (6.3% vs. 2.1%) (Roberts et al. 2017).

According to an analysis of pooled data from the 2012–2013 NSDUH, past-30-day use of cigars was lower among residents in rural areas than it was among those in urban areas in the Midwest (particularly in the West North Central division of the Midwest, which includes Iowa, Kansas, Minnesota, Missouri, North Dakota, Nebraska, and South Dakota) and in the South (particularly the South Atlantic division of the South, which includes Delaware, Florida, Georgia, Maryland, North Carolina, South Carolina, Virginia, and West Virginia), but pipe use did not differ by urban or rural areas in these two divisions (Roberts et al. 2016b). The PATH Study found that in 2013–2014, cigarillo and hookah smoking, along with dual use or polyuse of emerging tobacco products (e-cigarettes, cigarillos, or hookah), were all more prevalent among people in urban areas than they were among those in rural areas, but use of e-cigarettes, cigars, or pipes did not differ significantly across urban or rural areas (Roberts et al. 2017). Another study found no differences in use of noncigarette tobacco products (cigars, pipes, bidis, kreteks, or other) by rural or urban residence (Vander Weg et al. 2011).

According to data from the 2014–2015 TUS-CPS that were analyzed by Mumford and colleagues (2019), rural residents in the United States had a higher prevalence of ever use of e-cigarettes (rural: 9.4% vs. urban: 7.0%) and current use of e-cigarettes (rural: 2.8% vs. urban: 2.1%) compared with urban residents. Mumford and colleagues (2019) also examined urban–rural differences in e-cigarette use across the 10 regions designated by USDHHS; the largest urban–rural difference in ever use of e-cigarettes was observed in Region 2 (New York-New Jersey), in which 10.4% of rural residents and 5.0% of urban residents reported having ever used e-cigarettes. Furthermore, adjusted results indicated that current use of e-cigarettes was less likely among rural residents than it was among urban residents across northern and western parts of the United States (New England, East North Central, Heartland, North Central Mountain, Northwest, and Southwest Pacific regions) (aOR range = 0.61–0.79), but no significant differences were observed in the use of e-cigarettes between urban and rural residents in several regions (Mumford et al. 2019).

#### Patterns of Smoking Cessation

Using NSDUH data from 2010 to 2020, Parker and colleagues (2022) examined trends in quit ratios among people who smoked cigarettes and lived in rural and urban areas. In 2020, the prevalence of current cigarette smoking was higher among residents in rural areas (19.2%; 95% CI, 16.9%–21.7%) than it was among those in urban areas (14.4%; 95% CI, 13.3%–15.5%), but quit ratios were similar in rural (52.9%; 95% CI, 48.3–57.4) and urban (53.9%; 95% CI, 51.4–56.5) areas. Although quit ratios increased over time from 2010 to 2020, the adjusted odds of quitting across all years were lower among people who lived in rural areas than they were among those who lived in urban areas (aOR = 0.93; 95% CI, 0.89–0.98).

## Disparities in Exposure to Secondhand Tobacco Smoke

Millions of non-smoking people in the United States are exposed to secondhand tobacco smoke (CDC 2010). Disparities in exposure to secondhand tobacco smoke were highlighted in the 1998 Surgeon General’s report, Tobacco Use Among U.S. Racial/Ethnic Minority Groups–African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics (USDHHS 1998); the 2006 Surgeon General’s report, The Health Consequences of Involuntary Exposure to Tobacco Smoke (USDHHS 2006); and in NCI Tobacco Control Monograph 22, A Socioecological Approach to Addressing Tobacco-Related Health Disparities (NCI 2017). The 2006 Surgeon General’s report concluded that no amount of exposure to secondhand tobacco smoke is safe (USDHHS 2006). According to these reports, non-smoking people from lower SES backgrounds are disproportionately affected by exposure to secondhand tobacco smoke. However, from 1988 to 2014, exposure to secondhand tobacco smoke declined across age, racial and ethnic, and income groups (Tsai et al. 2018).

Exposure to secondhand tobacco smoke occurs in many settings: at home, in vehicles, in the workplace, and in other public places. The number of state and local comprehensive smokefree or clean indoor air policies and laws that prohibit smoking in all indoor public places and worksites, including restaurants and bars, has grown in the United States (Table 2.42) (see Chapter 7). As of January 2023, 62.5% of the total U.S. population is covered by 100% smokefree indoor air policies in bars, restaurants, and worksites (American Nonsmokers’ Rights Foundation 2023). However, some regions have lagged behind in adopting such policies (Hafez et al. 2019). In addition, these policies do not cover all populations equally (Gonzalez et al. 2013). Smokefree policies have the potential to be equity-producing for some populations. For example, among adults who smoke cigarettes, those who work in the accommodation and food services sector report lower levels of educational attainment and lower levels of income than those who work in other job sectors (Table 2.43) and thus, policies restricting smoking in restaurants and bars may be particularly important to protecting these workers from exposure to secondhand tobacco smoke.

### Exposure to Secondhand Tobacco Smoke in Homes

The home is the main setting in which youth are exposed to secondhand tobacco smoke and is also a major source of exposure to secondhand tobacco smoke among non-smoking adults (Yao et al. 2016). Although an increasing proportion of the population is covered by smokefree laws, millions of people who do not smoke continue to be exposed to secondhand tobacco smoke in private areas, such as homes and vehicles, that are not covered by such laws (King et al. 2014b). Using data from the 2011–2018 NYTS, Walton and colleagues (2020) estimated that self-reported exposure to secondhand tobacco smoke inside the home declined from 26.8% in 2011 to 20.9% in 2018 (p <0.001) among U.S. middle and high school students. However, in 2019, 25.3% (95% CI, 23.4–27.3) of U.S. middle and high school students (an estimated 6.7 million students) reported that someone had smoked tobacco products inside their respective homes while they were present during the past 7 days (Walton et al. 2020).

Table 2.42 Status of smokefree indoor air restrictions in private worksites, restaurants, and bars in the United States and U.S. territories as of June 30, 2021

Location | Private worksites | Restaurants | Bars
Alabama | Designated areas | None | None
Alaska | No provision | Designated areas | No provision
American Samoa | Banned | Banned | Banned
Arizona | Banned | Banned | Banned
Arkansas | Banned | Designated Areas | None
California | Banned | Banned | Banned
Colorado | Banned | Banned | Banned
Connecticut | Separate ventilated areas | Separate ventilated areas | Separate ventilated areas
Delaware | Banned | Banned | Banned
District of Columbia | Banned | Banned | Banned
Florida | Banned | Banned | None
Georgia | Designated areas | Designated areas | Designated areas
Guam | Designated smoking area | Banned | Banned
Hawai‘i | Banned | Banned | Banned
Idaho | Designated areas | Banned | None
Illinois | Banned | Banned | Banned
Indiana | Banned | Banned | None
Iowa | Banned | Banned | Banned
Kansas | Banned | Banned | Banned
Kentucky | No provision | No provision | No provision
Louisiana | Banned | Banned | None
Maine | Banned | Banned | Banned
Marshall Islands | Banned | Banned | Banned
Maryland | Banned | Banned | Banned
Massachusetts | Banned | Banned | Banned
Michigan | Banned | Banned | Banned
Minnesota | Banned | Banned | Banned
Mississippi | No provision | No provision | No provision
Missouri | Designated areas | Designated areas | Designated areas
Montana | Banned | Banned | Banned
Nebraska | Banned | Banned | Banned
Nevada | Banned | Banned | None
New Hampshire | Designated areas | Banned | No provision
New Jersey | Banned | Banned | Banned
New Mexico | Banned | Banned | Banned
New York | Banned | Banned | Banned
North Carolina | No provision | Banned | Banned
North Dakota | Banned | Banned | Banned
Northern Mariana Islands | Banned | Banned | No provision
Ohio | Banned | Banned | Banned
Oklahoma | Designated areas | Separate ventilated areas | None
Oregon | Banned | Banned | Banned
Palau | Banned | Designated smoking area | Designated smoking area
Pennsylvania | Banned | Separate ventilated areas | None
Puerto Rico | Banned | Banned | Banned
Rhode Island | Banned | Banned | Banned
South Carolina | No provision | No provision | No provision
South Dakota | Banned | Banned | Banned
Tennessee | Banned | Designated Areas | None
Texas | No provision | No provision | No provision
Utah | Banned | Banned | Banned
Vermont | Banned | Banned | Banned
Virgin Islands (U.S.) | Banned | Banned | Banned
Virginia | No provision | Separate ventilated areas | Separate ventilated areas
Washington | Banned | Banned | Banned
West Virginia | No provision | No provision | No provision
Wisconsin | Banned | Banned | Banned
Wyoming | No provision | No provision | No provision

Source: CDC (2023b).

Table 2.43 Characteristics of adults, 18 years of age and older, who smoked cigarettes, by industry sector; National Health Interview Survey (NHIS) 2020–2021, United States

Characteristics | People who work in the accommodation and food services sector: % (95% CI) | People who work in all other industry sectors: % (95% CI) | p-value^a^
Total | 15.6 (13.6–17.7) | 11.3 (10.9–11.8) | <0.001
Education
< High school diploma | 9.9 (5.7–14.0 | 6.3 (5.3–7.3)) | 0.103
High school diploma/GED | 36.2 (29.0–43.4) | 29.9 (28.0–31.8) | 0.094
> High school diploma | 53.5 (46.1–61.0) | 63.6 (61.6–65.6) | 0.010
Poverty status^b^
Poor | 19.7 (13.5–25.8) | 9.9 (8.6–11.1) | <0.002
Near poor | 28.3 (22.2–34.3) | 22.9 (21.2–24.7) | 0.100
Not poor | 52.1 (44.8–59.3) | 67.2 (65.1–69.3) | <0.001
Frequency of smoking
Every day | 78.1 (72.4–83.8) | 72.3 (70.4–74.1) | 0.054
Some days | 21.9 (16.2–27.5 | 27.7 (25.9–29.6 | 0.054
Number of cigarettes smoked per day
≤12 | 66.0 (58.2–73.9) | 56.2 (53.7–58.7) | 0.019
>12 | 34.0 (26.1–41.8) | 43.8 (41.3–46.3) | 0.019
Attempted to quit smoking^c^
Yes | 52.8 (43.3–62.3) | 49.9 (47.1–52.7) | 0.568
No | 47.2 (37.7–56.7) | 50.1 (47.3–52.9) | 0.568
Self-rated physical health^d^
Excellent/good | 89.0 (85.4−92.9) | 87.8 (86.5−89.1) | 0.573
Poor/fair | 11.0 (7.1−15.0) | 12.2 (10.9−13.5) | 0.573
Regularly having feelings of anxiety^e^
Yes | 73.5 (67.5–79.5) | 71.3 (69.4–73.3) | 0.501
No | 26.5 (20.5–32.5) | 28.7 (26.7–30.6) | 0.501
Regularly having feelings of depression^f^
Yes | 59.5 (52.6–66.4) | 49.7 (47.6–51.8) | 0.007
No | 40.5 (33.6–47.3) | 50.3 (48.2–52.4) | 0.007

Source: NHIS, National Center for Health Statistics, public use data, 2020–2021.

Notes: The 2021 NHIS public use data are the most recent to report industry/occupation information. This information was not included in the 2019 NHIS public use data. CI = confidence interval; GED = General Educational Development (certificate or diploma).

a Two-tailed t-tests were used to determine statistically significant differences in characteristics of people who smoked cigarettes in the accommodations and food service industry and people who smoked cigarettes in all other industries, combined. More information is available at Schiller (2011).

b Poverty status was based on family income and family size using poverty thresholds, as defined by the U.S. Census Bureau, for the previous calendar year. Poor was defined as being below the poverty threshold. Near poor was defined as a family income between 100% and 199% of the poverty threshold. Not poor was defined as a family income at least 200% of the poverty threshold. More information is available at National Center for Health Statistics (2009).

c Attempted to quit smoking was based on responses to the question, “During the past 12 months, have you stopped smoking for more than 1 day because you were trying to quit smoking?” This variable is based on data for only the year 2020.

d Physical health was based on responses to the question, “Would you say your health in general is excellent, very good, good, fair, or poor?”

e Answers to the following questions were used to assess regularly having feelings of anxiety: “How often do you feel worried, nervous or anxious? Would you say daily, weekly, monthly, a few times a year, or never?” and “Thinking about the last time you felt worried, nervous or anxious, how would you describe the level of these feelings? Would you say a little, a lot, or somewhere in between?”

f Answers to the following questions were used to assess regularly having feelings of depression: “How often do you feel depressed? Would you say daily, weekly, monthly, a few times a year, or never?” and “Thinking about the last time you felt depressed, how would you describe the level of these feelings? Would you say a little, a lot, or somewhere in between?”

King and colleagues (2014b) found that the greatest proportion of smokefree rules in the home occurred in households with no adults who smoked; the same pattern also emerged in the 2018–2019 data from TUS-CPS (Table 2.44). The prevalence of smokefree rules in homes with adults who did not smoke during 2018–2019 ranged from 89.3% (95% CI, 87.4–91.2) in Kentucky to 96.7% (95% CI, 95.8–97.6) in Idaho (Table 2.44). For households with at least one adult who smoked, the prevalence of smokefree rules in homes was lower than that in homes with adults who did not smoke. However, the prevalence of smokefree rules in homes with at least one person who smoked rose dramatically over time, from 9.6% (95% CI, 8.8–10.4) during 1992–1993 to 57.8% (95% CI, 56.8–58.8) during 2018–2019. By state, the prevalence of smokefree rules in homes in 2018–2019 with at least one adult who smoked ranged from 39.1% (95% CI, 34.0–44.3) in Kentucky to 80.8% (95% CI, 73.7–87.9) in Utah (Table 2.44). In all households, the prevalence of smokefree rules increased from 43.0% (95% CI, 42.1–43.9) during 1992–1993 to 89.1% (95% CI, 88.9–89.4) during 2018–2019 (Table 2.44).

One-quarter of the U.S. population, roughly 80 million people, resides in multi-unit housing, including apartment buildings (King et al. 2013a). An estimated 7 million of these people live in subsidized housing (U.S. Department of Housing and Urban Development n.d.). On February 2, 2017, the U.S. Department of Housing and Urban Development promulgated a final rule requiring public housing authorities to adopt smokefree policies (Federal Register 2016). The rule, which went into effect on July 30, 2018, requires more than 3,000 public housing authorities across the country to restrict smoking in all indoor areas and within 25 feet of buildings. However, this policy does not apply to all forms of subsidized, multi-unit housing, including Section 8.

One measure to evaluate the implementation of smokefree policies is the proportion of multi-unit housing residents exposed to incursions of secondhand tobacco smoke into their homes from nearby units or shared areas. Data on real-time transfer between smoking and smokefree units confirm that measurable units of PM2.5 (particulate matter 2.5) are detectable in adjacent smokefree units: 10.2 micrograms per cubic meter of air (μg/m^3^) in adjacent smokefree units, 18.9 μg/m^3^ in hallways, and 29.4 μg/m^3^ in smoke-permitted units (King et al. 2013a). A 2013 study using a random sample of U.S. multi-unit housing residents with children in the home and without smoking in the home determined that 25.2% of residents had experienced a recent incursion of secondhand tobacco smoke into their homes (Wilson et al. 2017).

### Exposure to Secondhand Tobacco Smoke in Vehicles

As of January 31, 2023, nine states (Arkansas, California, Illinois, Louisiana, Maine, Oregon, Utah, Vermont, and Virginia), Guam, the Northern Mariana Islands, and Puerto Rico had passed laws prohibiting smoking in personal vehicles when children are present (CDC 2023c). Using nationally representative data from the 2009–2010 and 2013–2014 National Adult Tobacco Survey, Kruger and colleagues (2016) estimated that from 2009–2010 to 2013–2014, the percentage of adults with 100% smokefree vehicle rules increased from 73.6% to 79.5% (p <0.05). Using data from the 2011–2018 NYTS, Walton and colleagues (2020) estimated that self-reported exposure to secondhand tobacco smoke inside vehicles declined from 30.2% in 2011 to 19.8% in 2018 among U.S. middle and high school students. However, in 2019, 23.3% (95% CI, 21.4–25.4) of U.S. middle and high school students (an estimated 6.1 million students) reported that someone had smoked tobacco products inside a vehicle while they were present during the past 7 days (Walton et al. 2020).

### Exposure to Secondhand Tobacco Smoke in Correctional Settings

An estimated 2.1 million people were incarcerated in the United States in 2019 (Minton et al. 2021). An estimated 50% of state and federal inmates in 2004 currently smoked cigarettes (Binswanger et al. 2009; Kennedy et al. 2016). In a national study, adults who were incarcerated were more likely to have relatively lower levels of educational attainment and income and to have mental health and other chronic health issues compared with adults who were not incarcerated (James and Glaze 2006). These factors are independently associated with tobacco use, putting adults who are incarcerated at high risk of tobacco use.

Table 2.44 Percentage of households with a smokefree home rule,^a^ by location and smoking status of an adult living in the household;^b^ Tobacco Use Supplement to the Current Population Survey (TUS-CPS) 1992–1993 and 2018–2019, United States

Location | All households: % (95% CI) | | Households with adults who did not smoke: % (95% CI) | | Household with at least one adult who did smoke: % (95% CI)
Location | 1992–1993 | 2018–2019c | 1992–1993 | 2018–2019^c^ | 1992–1993 | 2018–2019c
Alabama | 38.7 (34.0–43.4) | 85.2 (82.5–87.9) | 54.1 (48.4–59.8) | 93.3 (91.4–95.2) | 6.7 (5.1–8.3) | 45.2 (40.1–50.3)
Alaska | 50.8 (46.9–54.7) | 91.1 (89.5–92.7) | 68.0 (63.8–72.1) | 94.9 (93.5–96.3) | 14.1 (8.3–19.8) | 71.6 (64.5–78.6)
Arizona | 54.1 (50.6–57.5) | 92.5 (91.2–93.9) | 68.2 (63.4–73.0) | 95.8 (94.6–97.0) | 17.2 (14.6–19.8) | 67.7 (60.8–74.7)
Arkansas | 33.1 (29.9–36.2) | 84.9 (82.8–87.0) | 46.7 (42.3–51.1) | 91.6 (89.9–93.2) | 5.3 (3.3–7.3) | 51.5 (45.3–57.8)
California | 59.0 (57.3–60.7) | 92.9 (92.3–93.6) | 71.6 (70.1–73.1) | 94.8 (94.2–95.3) | 19.0 (16.6–21.3) | 73.3 (69.3–77.2)
Colorado | 47.8 (44.8–50.8) | 91.3 (89.5–93.1) | 62.9 (59.3–66.6) | 94.8 (93.6–96.0) | 10.2 (6.6–13.8) | 61.9 (52.7–71.1)
Connecticut | 44.7 (42.2–47.2) | 90.5 (88.6–92.4) | 58.4 (54.6–62.3) | 94.0 (92.3–95.6) | 11.7 (8.8–14.7) | 60.1 (51.0–69.1)
Delaware | 40.0 (36.7–43.3) | 89.6 (87.4–91.8) | 52.2 (48.8–55.5) | 93.0 (91.0–94.9) | 9.9 (5.2–14.6) | 63.8 (54.8–72.8)
District of Columbia | 41.3 (37.6–43.3) | 88.3 (86.8–89.8) | 52.8 (48.5–57.0) | 93.3 (92.2–94.5) | 5.5 (1.6–9.5) | 49.6 (43.0–56.3)
Florida | 50.1 (48.2–51.9) | 91.7 (90.9–92.5) | 64.8 (62.8–66.7) | 95.2 (94.6–95.9) | 13.2 (10.6–15.7) | 64.8 (59.9–69.7)
Georgia | 41.4 (38.4–44.3) | 88.1 (86.5–89.6) | 55.1 (51.2–59.0) | 93.3 (92.2–94.4) | 7.9 (4.9–10.9) | 53.4 (46.0–60.8)
Hawai‘i | 51.2 (47.1–55.4) | 88.0 (85.7–90.3) | 64.6 (59.5–69.7) | 90.2 (87.9–92.6) | 12.7 (8.6–16.7) | 68.3 (59.4–77.2)
Idaho | 50.0 (45.1–54.9) | 93.6 (92.2–94.9) | 66.1 (60.5–71.7) | 96.7 (95.8–97.6) | 11.5 (8.9–14.1) | 70.5 (64.4–76.5)
Illinois | 38.5 (35.6–41.5) | 88.5 (87.3–89.7) | 51.3 (48.3–54.2) | 94.1 (93.1–95.2) | 7.2 (4.9–9.5) | 51.9 (46.1–57.7)
Indiana | 33.9 (30.9–36.9) | 83.9 (81.2–86.6) | 47.6 (43.4–51.8) | 91.4 (89.7–93.1) | 7.8 (4.5–11.1) | 46.8 (39.2–54.5)
Iowa | 35.9 (33.1–38.8) | 87.8 (85.8–89.8) | 48.0 (44.4–51.6) | 93.3 (91.6–95.1) | 5.6 (3.7–7.4) | 60.3 (52.7–67.9)
Kansas | 39.6 (36.0–43.2) | 87.3 (85.3–89.4) | 54.9 (51.6–58.2) | 92.3 (90.6–93.9) | 4.9 (3.2–6.7) | 57.0 (50.4–63.7)
Kentucky | 25.6 (21.4–29.8) | 79.0 (76.4–81.6) | 39.2 (33.3–45.0) | 89.3 (87.4–91.2) | 3.6 (2.3–5.0) | 39.1 (34.0–44.3)
Louisiana | 37.0 (33.3–40.7) | 86.8 (85.2–88.4) | 47.8 (44.1–51.5) | 93.1 (91.8–94.5) | 11.6 (7.1–16.1) | 54.3 (47.9–60.7)
Maine | 39.5 (34.6–44.4) | 86.8 (84.7–88.9) | 57.5 (51.7–63.4) | 93.1 (91.3–95.0) | 8.1 (5.1–11.1) | 57.8 (48.9–66.8)
Maryland | 42.4 (38.9–45.8) | 91.7 (90.0–93.4) | 56.7 (53.2–60.2) | 94.5 (93.0–96.0) | 6.3 (3.1–9.5) | 68.7 (61.2–76.2)
Massachusetts | 40.2 (38.1–42.3) | 91.0 (89.4–92.5) | 51.2 (49.1–53.2) | 94.0 (92.6–95.3) | 10.0 (7.8–12.2) | 63.6 (56.0–71.1)
Michigan | 35.0 (33.1–36.9) | 84.4 (82.6–86.1) | 49.1 (46.8–51.3) | 91.6 (90.0–93.1) | 6.1 (4.9–7.3) | 47.5 (41.8–53.1)
Minnesota | 39.6 (37.8–41.4) | 91.4 (89.4–93.4) | 53.8 (50.9–56.6) | 95.1 (93.5–96.6) | 7.8 (5.2–10.3) | 68.3 (62.9–73.6)
Mississippi | 40.9 (37.1–44.7) | 82.8 (81.4–84.2) | 53.9 (49.1–58.6) | 91.2 (90.1–92.3) | 9.1 (6.3–12.0) | 48.0 (41.7–54.2)
Missouri | 34.1 (30.1–38.1) | 83.8 (82.3–85.3) | 46.0 (41.7–50.4) | 91.2 (89.7–92.7) | 7.6 (4.4–10.8) | 44.1 (36.6–51.6)
Montana | 42.8 (38.8–46.7) | 91.6 (90.2–93.0) | 56.8 (53.1–60.5) | 96.0 (95.0–97.0) | 7.4 (5.3–9.4) | 67.2 (61.4–73.0)
Nebraska | 40.0 (36.3–43.7) | 90.7 (88.8–92.6) | 52.2 (47.6–56.8) | 94.4 (92.9–96.0) | 8.6 (6.7–10.6) | 70.1 (63.4–76.8)
Nevada | 45.5 (42.5–48.4) | 90.3 (88.7–91.9) | 62.5 (59.4–65.6) | 93.7 (92.2–95.2) | 10.3 (6.8–13.7) | 70.2 (63.5–76.8)
New Hampshire | 38.3 (34.7–42.0) | 91.3 (89.6–93.0) | 51.5 (47.4–55.6) | 95.0 (93.5–96.6) | 7.3 (3.9–10.8) | 68.9 (62.9–75.0)
New Jersey | 45.5 (43.2–47.7) | 90.1 (88.4–91.8) | 58.3 (56.3–60.3) | 93.0 (91.6–94.5) | 10.1 (8.5–11.7) | 58.7 (50.3–67.2)
New Mexico | 45.4 (40.8–50.0) | 88.4 (86.3–90.5) | 58.8 (53.1–64.6) | 93.3 (91.5–95.0) | 11.4 (5.3–17.5) | 55.4 (49.5–61.3)
New York | 41.4 (39.6–43.2) | 87.7 (86.5–88.9) | 53.7 (52.2–55.2) | 92.2 (91.2–93.2) | 8.1 (6.2–10.0) | 49.5 (44.7–54.3)
North Carolina | 34.1 (32.3–35.9) | 87.8 (86.0–89.5) | 46.2 (44.1–48.4) | 94.0 (92.9–95.1) | 8.6 (7.2–10.0) | 51.7 (45.2–58.2)
North Dakota | 40.9 (36.8–45.0) | 88.9 (86.8–91.1) | 53.0 (48.4–57.6) | 93.8 (91.8–95.8) | 8.3 (6.1–10.5) | 66.1 (57.7–74.6)
Ohio | 35.0 (33.5–36.5) | 82.0 (80.6–83.4) | 47.9 (46.0–49.8) | 90.9 (89.6–92.2) | 6.0 (4.7–7.2) | 41.2 (36.8–45.6)
Oklahoma | 39.1 (35.0–43.1) | 85.4 (83.6–87.2) | 55.2 (50.6–59.7) | 92.4 (91.0–93.7) | 6.0 (4.6–7.5) | 54.0 (46.9–61.1)
Oregon | 49.8 (45.8–53.8) | 93.7 (92.1–95.3) | 64.5 (60.3–68.6) | 96.1 (95.0–97.1) | 13.1 (7.9–18.4) | 78.4 (71.7–85.1)
Pennsylvania | 39.6 (37.9–41.3) | 87.3 (85.7–88.9) | 52.7 (50.8–54.5) | 92.7 (91.2–94.2) | 7.9 (6.3–9.6) | 57.5 (52.1–62.9)
Rhode Island | 38.9 (34.1–43.8) | 91.2 (89.3–93.0) | 52.6 (46.7–58.5) | 93.1 (91.3–94.9) | 6.6 (3.8–9.4) | 72.4 (62.7–82.2)
South Carolina | 39.9 (37.3–42.5) | 88.1 (86.1–90.1) | 54.3 (51.0–57.7) | 94.2 (92.5–96.0) | 7.4 (5.4–9.4) | 52.0 (44.7–59.4)
South Dakota | 36.7 (34.1–39.2) | 89.3 (87.3–91.4) | 50.0 (47.1–52.9) | 93.9 (92.5–95.3) | 5.2 (3.4–7.1) | 68.3 (59.9–76.7)
Tennessee | 33.9 (30.5–37.3) | 85.6 (84.2–87.1) | 48.8 (44.6–53.1) | 93.5 (92.4–94.5) | 4.6 (3.6–5.5) | 48.6 (42.4–54.7)
Texas | 46.3 (43.6–49.0) | 91.6 (90.8–92.5) | 60.3 (57.6–63.0) | 94.7 (94.1–95.3) | 10.6 (8.5–12.6) | 65.7 (61.0–70.4)
Utah | 69.4 (65.5–73.2) | 94.5 (92.8–96.1) | 82.8 (80.4–85.2) | 95.7 (94.3–97.1) | 20.9 (13.1–28.7) | 80.8 (73.7–87.9)
Vermont | 39.0 (35.3–42.7) | 91.4 (90.1–92.7) | 54.6 (50.3–58.9) | 95.7 (94.7–96.8) | 8.3 (4.6–11.9) | 60.2 (53.0–67.3)
Virginia | 39.0 (35.9–42.1) | 90.5 (88.6–92.4) | 53.8 (49.5–58.0) | 94.4 (93.2–95.7) | 7.4 (5.1–9.7) | 58.1 (50.9–65.3)
Washington | 54.3 (50.4–58.3) | 93.2 (91.6–94.7) | 69.5 (65.0–74.0) | 95.9 (94.9–96.9) | 16.9 (13.4–20.4) | 71.2 (63.5–78.9)
West Virginia | 27.9 (24.0–31.8) | 78.3 (76.3–80.3) | 41.8 (36.9–46.7) | 90.0 (88.9–91.2) | 4.0 (2.8–5.2) | 42.6 (38.3–47.0)
Wisconsin | 36.5 (33.3–39.6) | 89.3 (88.0–90.7) | 50.4 (47.4–53.3) | 94.0 (93.0–95.1) | 5.9 (4.3–7.6) | 64.0 (58.1–69.9)
Wyoming | 38.5 (34.5–42.4) | 90.2 (88.4–91.9) | 52.8 (48.6–57.1) | 94.8 (93.6–96.0) | 6.2 (4.1–8.2) | 65.9 (59.7–72.1)
Overall | 43.0 (42.1–43.9) | 89.1 (88.9–89.4) | 56.7 (55.9–57.5) | 93.7 (93.5–94.0) | 9.6 (8.8–10.4) | 57.8 (56.8–58.8)

Source: Data for TUS-CPS 1992–1993 were published in King and colleagues (2014, p. 767); TUS-CPS, public use data, 2018–2019.

Notes:CI = confidence interval.

a Households were considered to have had a smokefree home rule if all adult respondents, 18 years of age and older, in the household reported that no one was allowed to smoke anywhere inside the home at any time.

b Households were considered to have had at least one adult who smoked if at least one adult resident, 18 years of age or older, reported having smoked at least 100 cigarettes in their lifetime and smoking “every day” or “some days” at the time of the survey.

c Results of TUS-CPS 2018–2019 were limited to interviewed self-respondents who were 18 years of age and older and living in civilian households (N = 137,471). Statistically significant increases, both overall and in all states (p <0.05), were observed from 1992–1993 to 2018–2019.

Few smokefree policies were established in prisons and jails before the 1980s, but by 2007, an estimated 87% of U.S. prisons and jails prohibited indoor smoking at their facilities (Kauffman et al. 2008). Effective January 2015, the Federal Bureau of Prisons (BOP) prohibited smoking of tobacco in any form in and on the grounds of BOP institutions and offices, allowing BOP staff and visitors to smoke only in designated outdoor areas (Federal Bureau of Prisons 2015).

In their review of smokefree policies in correctional facilities, Kennedy and colleagues (2015) concluded that concerns remain about consistent implementation and enforcement practices for smokefree policies in individual prisons and jails. However, when enforced, such policies can dramatically reduce exposure to secondhand tobacco smoke among inmates, visitors, and staff. For example, Proescholdbell and colleagues (2008) measured levels of PM2.5 in indoor areas of prisons in North Carolina before and after implementation of a statewide law in 2006 requiring all indoor prison areas to be smokefree for prisoners, staff, and visitors. They found that indoor PM2.5 concentrations declined 77% after implementation—from an average of 93.11 μg/m^3^ in locations that allowed smoking to an average of 21.82 μg/m^3^ in these locations after the tobacco use policy was in effect. After excluding a site with known noncompliance with the statewide policy, results demonstrated a 91% reduction in mean PM2.5 concentrations before and after policy implementation.

### Exposure to Secondhand Tobacco Smoke by Age and Race and Ethnicity

In their examination of data from the 2000 and 2010 NHIS, Yao and colleagues (2016) found that self-reported exposure to secondhand tobacco smoke decreased for all racial and ethnic groups from 2000 to 2010, but sociodemographic differences remained for some groups over time. For example, non-Hispanic Black adults and youth were more likely to be exposed to secondhand tobacco smoke than their non-Hispanic White counterparts in 2010 (Yao et al. 2016).

Based on available laboratory limits of detection and research, exposure to secondhand tobacco smoke has historically been defined using a serum (blood) cotinine concentration range from the limit of detection of 0.05 to 10 nanograms of cotinine per milliliter of serum (ng/mL) (Tsai et al. 2021). Cotinine is a metabolite of nicotine and is widely used as a biomarker of nicotine exposure. As such, cotinine cannot distinguish between nicotine exposure from different sources, such as from exposure to secondhand tobacco smoke or from other tobacco products, such as e-cigarettes. Serum cotinine concentrations greater than 10 ng/mL are associated with recent active smoking. Tobacco biomarkers have also been used locally in surveillance efforts to identify populations at risk of high exposure to secondhand tobacco smoke (Benowitz et al. 2009; Chang et al. 2021). Data on exposure to secondhand tobacco smoke reported by Tsai and colleagues (2018) corroborated the finding that non-Hispanic Black people who do not smoke have a higher prevalence of having a serum cotinine concentration of 0.05–10 ng/mL compared with Mexican American people who do not smoke and non-Hispanic White people who do not smoke (Tables 2.45 and 2.46).

According to NHANES data from 1988 to 2018, the percentage of people who did not smoke and had serum cotinine levels 0.05–10 ng/mL decreased among children 3–19 years of age; adults 20 years of age and older; and people who identified as non-Hispanic White, non-Hispanic Black, and Mexican American (Figures 2.19 and 2.20). However, these declines were more pronounced from 1988 to 2010; since 2011–2012, the data suggest that little progress has been made in reducing exposure to secondhand tobacco smoke. From 1988 to 2018, declines varied across populations, thus indicating a disparity in exposure to secondhand tobacco smoke among people who did not smoke. By age, NHANES data on serum cotinine levels from 1988–1991 to 2017–2018 revealed that declines in exposure to secondhand tobacco smoke were greater among adults 20 years of age and older (declined by 66.2 percentage points; from 87.4% in 1988–1991 to 21.2% in 2017–2018) than they were among children and adolescents 3–19 years of age (declined by 51.9 percentage points; from 87.6% in 1988–1991 to 35.7% in 2017–2018) (Table 2.45). The absolute disparity in exposure to second-hand tobacco smoke between adults and children and adolescents increased from 1988 to 1991 (children and adolescents’ exposure was 0.2 percentage points higher than that of adults) to 2017–2018 (children and adolescents’ exposure was 14.5 percentage points higher than that of adults).

By race and ethnicity, NHANES data on serum cotinine levels for 1988–1991 and 2017–2018 revealed that declines in exposure to second-hand tobacco smoke were greater among non-Hispanic White (from 86.9% in 1988–1991 to 22.0% in 2017–2018) and Mexican American (from 83.8% in 1988–1991 to 16.6% in 2017–2018) people who did not smoke than they were among non-Hispanic Black people who did not smoke (from 94.4% in 1988–1991 to 48.0% in 2017–2018) (Table 2.45). Between 1988–1991 and 2017–2018, the absolute disparity in exposure to secondhand tobacco smoke among non-Hispanic Black people who did not smoke increased compared with Mexican American (by 20.8 percentage points) and White (by 18.5 percentage points) people who did not smoke. During 2017–2018, exposure to secondhand tobacco smoke was more than two times higher among non-Hispanic Black people who did not smoke than it was among non-Hispanic White and Mexican American people who did not smoke.

Table 2.45 Percentage of people who did not smoke^a^ and had serum cotinine levels 0.05–10 ng/mL, by selected demographic characteristics; National Health and Nutrition Examination Survey (NHANES) 1988–2018, United States A. 1988–2006

A 1988–2006

Characteristics | 1988–1991:^b^ % (95% CI) | 1991–1994:^b^ % (95% CI) | 1999–2000: % (95% CI) | 2001–2002: % (95% CI) | 2003–2004: % (95% CI) | 2005–2006: % (95% CI)
Age group (in years)
3–19 | 87.6 (83.9–91.3) | 82.1 (77.8–86.4) | 64.1 (57.5–70.3) | 51.7 (42.8–60.5) | 61.8 (54.0–69.0) | 48.3 (43.4–53.1)
≥20 | 87.4 (85.3–89.6) | 79.0 (75.2–82.8) | 48.0 (42.7–53.4) | 37.8 (31.9–44.1) | 42.4 (35.3–49.9) | 35.8 (32.5–39.2)
Race and ethnicity^c^
Non-Hispanic White | 86.9 (83.8–90.0) | 78.9 (74.8–83.0) | 49.6 (42.5–56.7) | 36.3 (29.8–43.4) | 46.1 (37.1–55.4) | 36.6 (32.5–40.9)
Non-Hispanic Black | 94.4 (91.4–97.4) | 92.7 (91.0–94.3) | 74.2 (70.1–77.9) | 71.8 (66.4–76.7) | 68.2 (59.4–75.9) | 60.2 (52.9–67.0)
Mexican American | 83.8 (76.7–90.9) | 70.1 (64.1–76.2) | 44.3 (37.5–51.2) | 39.9 (30.8–49.7) | 34.8 (26.8–43.9) | 33.8 (26.9–41.5)
Poverty status
Below the poverty level^d^ | 91.4 (87.2–95.7) | 86.2 (81.9–90.4) | 71.6 (64.3–78.0) | 60.2 (46.7–72.4) | 64.0 (55.3–71.9) | 62.7 (56.9–68.2)
At or above the poverty level | 86.6 (83.7–89.6) | 78.7 (74.8–82.7) | 48.8 (42.9–54.8) | 38.4 (33.1–44.1) | 45.0 (38.1–52.1) | 35.9 (32.8–39.1)
Unspecified | 89.9 (85.5–94.4) | 80.6 (70.5–90.8) | 53.5 (48.4–58.5) | 44.1 (33.2–55.6) | 50.6 (36.8–64.2) | 42.0 (29.8–55.3)
Education (≥25 years of age)
≤Grade 11 | 86.0 (83.1–89.0) | 78.7 (74.6–82.9) | 53.9 (48.7–58.9) | 50.8 (44.3–57.3) | 48.8 (43.0–54.7) | 43.0 (36.8–49.4)
High school diploma or equivalent | 91.4 (88.3–94.5) | 82.0 (77.8–86.1) | 51.6 (44.5–58.6) | 46.1 (37.5–54.9) | 50.1 (39.9–60.2) | 41.8 (35.2–48.7)
Some college or associate degree | 84.7 (81.0–88.5) | 77.7 (71.3–84.1) | 48.2 (40.9–55.6) | 33.7 (26.4–41.9) | 42.7 (32.6–53.5) | 37.1 (32.2–42.3)
≥College diploma | 83.8 (78.1–89.5) | 73.2 (68.0–78.4) | 35.2 (27.9–43.3)

B 2007–2018

Characteristics | 2007–2008: % (95% CI) | 2009–2010: % (95% CI) | 2011–2012: % (95% CI) | 2013–2014: % (95% CI) | 2015–2016: % (95% CI) | 2017–2018: % (95% CI)
Age group (in years)
3–19 | 50.2 (43.2–57.3) | 38.9 (34.1–43.9) | 37.3 (32.2–42.7) | 35.0 (28.7–41.8) | 35.3 (31.0–39.8) | 35.7 (32.0–39.6)
≥20 | 36.7 (32.1–41.4) | 27.3 (24.5–30.2) | 21.2 (18.8–23.9) | 22.0 (18.4–26.1) | 21.1 (17.7–24.9) | 21.2 (18.1–24.6)
Race and ethnicity^c^
Non-Hispanic White | 40.1 (32.5–48.2) | 27.5 (24.0–31.3) | 21.8 (18.9–25.0) | 21.4 (16.1–27.8) | 22.3 (17.7–27.7) | 22.0 (18.6–25.9)
Non-Hispanic Black | 55.9 (50.6–61.2) | 55.3 (47.6–62.8) | 46.7 (38.4–55.1) | 50.3 (44.8–55.8) | 45.7 (40.0–51.5) | 48.0 (41.5–54.6)
Mexican American | 28.5 (23.4–34.2) | 24.8 (20.6–29.6) | 23.8 (17.2–31.9) | 20.0 (16.1–24.6) | 20.6 (16.7–25.2) | 16.6 (12.5–21.8)
Poverty status
Below the poverty level^d^ | 60.5 (54.9–65.9) | 50.1 (45.1–55.1) | 43.1 (37.6–48.8) | 47.9 (42.2–53.7) | 41.0 (33.5–49.0) | 44.9 (38.4–51.5)
At or above the poverty level | 36.9 (31.5–42.6) | 27.0 (23.7–30.5) | 21.2 (18.9–23.6) | 21.2 (17.4–25.7) | 21.5 (17.8–25.7) | 21.4 (18.9–24.0)
Unspecified | 39.6 (31.2–48.7) | 30.4 (24.6–37.0) | 31.3 (22.7–41.5) | 23.3 (17.6–30.1) | 28.9 (24.0–34.3) | 26.6 (20.5–33.7)
Education (≥25 years of age)
≤Grade 11 | 45.1 (39.3–50.9) | 38.4 (33.3–43.8) | 27.6 (23.9–31.7) | 30.7 (25.4–36.5) | 25.5 (18.5–33.9) | 26.8 (21.2–33.2)
High school diploma or equivalent | 41.4 (33.5–49.9) | 33.3 (30.2–36.6) | 27.5 (21.9–34.0) | 28.8 (21.7–37.0) | 31.4 (26.8–36.4) | 24.9 (19.2–31.6)
Some college or associate degree | 37.6 (31.2–44.4) | 25.2 (20.5–30.7) | 21.2 (17.8–24.9) | 23.5 (19.2–28.5) | 24.3 (19.4–29.9) | 24.3 (20.0–29.2)
≥College diploma | 22.0 (17.6–27.1) | 15.5 (11.6–20.4) | 11.8 (9.1–14.4) | 10.8 (8.1–14.3) | 8.9 (6.6–11.8) | 11.1 (8.5–14.4)

Source: NHANES, National Center for Health Statistics, public use data, 1988–2018.

Notes:CI = confidence interval; MEC = Mobile Examination Center; ng/mL = nanograms per milliliter.

a People who did not smoke were defined by specific age groups as follows: children 3–11 years of age with serum cotinine ≤10 ng/mL; adolescents 12–19 years of age with serum cotinine ≤10 ng/mL and who did not report smoking during the past 30 days or using any nicotine-containing products during the past 5 days at the MEC interview; and adults 20 years of age and older with serum cotinine ≤10 ng/mL and who did not report currently smoking or using any nicotine-containing products during the past 5 days at the MEC interview.

b Serum cotinine levels were available for NHANES III participants 4 years of age and older.

c Data by race and ethnicity were limited to the three racial and Hispanic origin groups available across all survey cycles: people who were non-Hispanic White, non-Hispanic Black, or Mexican American.

d Income-to-poverty ratio <1.0.

Table 2.46 Percentage of people who did not smoke^a^ and had serum cotinine levels 0.05–10 ng/mL, by age group and race and Hispanic origin;^b^ National Health and Nutrition Examination Survey (NHANES) 1988–2018, United States A. 1988–2006

A 1988–2006

| 1988–1991:^c^ % (95% CI) | 1991–1994:^c^ % (95% CI) | 1999–2000: % (95% CI) | 2001–2002: % (95% CI) | 2003–2004: % (95% CI) | 2005–2006: % (95% CI)
3–19 years of age
Non-Hispanic White | 86.2 (80.6–91.8) | 81.6 (76.3–87.0) | 62.3 (51.7–71.8) | 47.4 (36.0–59.1) | 63.5 (52.8–73.0) | 47.5 (41.7–53.4)
Non-Hispanic Black | 95.1 (91.0–99.2) | 94.9 (92.6–97.1) | 83.3 (79.2–86.7) | 80.5 (75.5–84.7) | 78.4 (69.3–85.4) | 69.8 (63.6–75.3)
Mexican American | 84.8 (78.0–91.6) | 71.3 (65.7–77.0) | 48.7 (41.1–56.3) | 43.4 (34.7–52.5) | 39.4 (30.9–48.5) | 33.0 (24.2–43.2)
≥20 years of age
Non-Hispanic White | 87.1 (84.5–89.6) | 78.0 (73.3–82.6) | 45.6 (39.1–52.1) | 32.8 (26.5–39.8) | 40.6 (31.9–50.0) | 33.2 (29.3–37.4)
Non-Hispanic Black | 94.0 (91.4–96.6) | 91.2 (89.4–92.9) | 68.7 (62.8–74.0) | 66.4 (60.2–72.1) | 61.6 (52.4–70.0) | 55.4 (47.5–63.1)
Mexican American | 83.2 (75.7–90.6) | 69.4 (62.6–76.2) | 41.2 (34.3–48.5) | 37.6 (27.4–49.0) | 31.9 (23.7–41.3) | 34.2 (27.9–41.2)

B 2007–2018

| 2007–2008: % (95% CI) | 2009–2010: % (95% CI) | 2011–2012: % (95% CI) | 2013–2014: % (95% CI) | 2015–2016: % (95% CI) | 2017–2018: % (95% CI)
3–19 years of age
Non-Hispanic White | 53.5 (42.3–64.5) | 37.4 (31.9–43.3) | 36.6 (31.3–42.4) | 34.0 (23.9–45.8) | 34.2 (26.4–43.0) | 38.5 (32.6–44.7)
Non-Hispanic Black | 62.5 (53.5–70.7) | 64.9 (56.0–73.0) | 61.1 (50.3–70.9) | 60.9 (51.5–69.6) | 61.1 (53.5–68.2) | 58.6 (49.9–66.9)
Mexican American | 29.4 (21.4–39.1) | 25.2 (21.7–29.1) | 23.6 (15.9–33.6) | 21.4 (15.6–28.6) | 27.1 (20.8–34.4) | 20.7 (14.4–28.8)
≥20 years of age
Non-Hispanic White | 36.3 (29.6–43.5) | 25.0 (21.5–28.7) | 17.9 (14.3–22.1) | 18.1 (13.8–23.3) | 19.3 (15.0–24.6) | 18.0 (14.7–22.0)
Non-Hispanic Black | 52.2 (46.6–57.8) | 50.5 (42.4–58.5) | 39.4 (32.9–46.3) | 45.5 (40.4–50.8) | 38.8 (33.5–44.3) | 43.3 (37.0–49.9)
Mexican American | 28.0 (23.5–32.9) | 24.5 (19.5–30.4) | 23.9 (17.4–31.9) | 19.2 (15.3–23.7) | 16.9 (13.9–20.5) | 14.3 (10.5–19.1)

Source: NHANES, National Center for Health Statistics, public use data, 1988–2018.

Notes:CI = confidence interval; MEC = Mobile Examination Center; ng/mL = nanograms per milliliter.

a People who did not smoke were defined by specific age groups as follows: children 3–11 years of age with serum cotinine ≤10 ng/mL; adolescents 12–19 years of age with serum cotinine ≤10 ng/mL and who did not report smoking during the past 30 days or using any nicotine-containing products during the past 5 days at the MEC interview; and adults 20 years of age and older with serum cotinine ≤10 ng/mL and who did not report currently smoking or using any nicotine-containing products during the past 5 days at the MEC interview.

b Data by race and ethnicity were limited to the three racial and Hispanic origin groups available across all survey cycles: people who were non-Hispanic White, non-Hispanic Black, or Mexican American.

c Serum cotinine levels were available for NHANES III participants 4 years of age and older.

Figure 2.19 Trends in the prevalence of people who did not smoke^a^ a People who did not smoke were defined by specific age groups as follows: children 3–11 years of age with serum cotinine ≤10 ng/mL; adolescents 12–19 years of age with serum cotinine ≤10 ng/mL and who did not report smoking during the past 30 days or using any nicotinecontaining products during the past 5 days at the MEC interview; and adults 20 years of age and older with serum cotinine ≤10 ng/mL and who did not report currently smoking or using any nicotine-containing products during the past 5 days at the MEC interview. and had serum cotinine levels 0.05–0.10 ng/mL, by age group; National Health and Nutrition Examination Survey (NHANES) 1988–1994 and 1999–2018, United States

Notes: MEC = Mobile Examination Center; ng/mL = nanograms per milliliter.

^b^Serum cotinine levels were available for NHANES III participants 4 years of age and older.

From 1988-1991 to 2017-2018, the prevalence of people who did not smoke and had serum cotinine levels 0.05-0.10 ng/mL generally decreased consistently, except for moderate increases in 2003-2004 and in 2007-2008, among people in two age groups: 3-19 years of age and 20 years of age and older. Such prevalence was consistently higher over time in the younger age group than in the older age group. Figure note “b” offers more details about the dataset for 1988-1991 and 1991-1994

Source: NHANES, National Center for Health Statistics, public use data, 1988–2018.

When examining exposure to secondhand tobacco smoke by race and ethnicity and age, more non-Hispanic White and non-Hispanic Black children 3–19 years of age were exposed to secondhand tobacco smoke than their counterparts 20 years of age and older (Table 2.46). Exposure to secondhand tobacco smoke did not differ by age group among Mexican American people.

Among people who did not smoke, self-reported exposure to secondhand tobacco smoke at a job during the past 7 days (among adults 20 years and older) during 2017–2018 was higher among Mexican American people (12.1%; 95% CI, 9.3–15.5) than it was among non-Hispanic White (5.3%; 95% CI, 3.5–8.2) and non-Hispanic Black (4.6%; 95% CI, 2.9–7.2) people (Table 2.47). Agaku and colleagues (2019) found that in both 2000 and 2010, Hispanic and non-Hispanic Asian youth were less likely than non-Hispanic White youth to be exposed to secondhand tobacco smoke at home. This finding is consistent with findings from King and colleagues (2013b), who noted that smokefree rules were present most often in Hispanic (87.7%) and non-Hispanic Asian (90.6%) households.

Advanced laboratory techniques in recent years have lowered the lower limit of serum cotinine detection from the initial limit of 0.05 ng/mL to a new limit of 0.015 ng/mL (CDC 2005; Pirkle et al. 2006). As such, questions have arisen about whether the current established definitions of exposure to secondhand tobacco smoke (0.05–10 ng/mL) should be re-evaluated (Tsai et al. 2021). Changes in the definition of exposure to secondhand tobacco smoke among the U.S. population using the lower limit of detection could have implications for trends and prevalence estimates (Tsai et al. 2018).

Using data from the 2011–2018 NHANES, Tsai and colleagues (2018) examined the implications of redefining exposure to secondhand tobacco smoke to include serum cotinine values from 0.015 to 10 ng/mL. This expanded definition more than doubled the estimated proportion of people in the United States exposed to secondhand tobacco smoke. The percentage of people 3 years of age and older who did not smoke and had levels of serum cotinine in the existing range (0.05–10 ng/mL) was similar during 2011–2012 (25.3%) and 2017–2018 (24.6%). However, using the expanded definition, the percentage of people who did not smoke and were exposed to secondhand tobacco smoke (serum cotinine 0.015−10 ng/mL) declined from 2011–2012 (58.3%) to 2017–2018 (52.3%), which suggests a reduction in exposure to secondhand tobacco smoke at the population level, especially among those experiencing lower levels of exposure (Tsai et al. 2018).

Figure 2.20 Trends in the prevalence of people who did not smoke^a^ a People who did not smoke were defined by specific age groups as follows: children 3–11 years of age with serum cotinine ≤10 ng/mL; adolescents 12–19 years of age with serum cotinine ≤10 ng/mL and who did not report smoking during the past 30 days or using any nicotinecontaining products during the past 5 days at the MEC interview; and adults 20 years of age and older with serum cotinine ≤10 ng/mL and who did not report currently smoking or using any nicotine-containing products during the past 5 days at the MEC interview. and had serum cotinine levels 0.05–0.10 ng/mL, by race and ethnicity;^b^ b Data by race and ethnicity were limited to the three racial and Hispanic origin groups available across all survey cycles: people who were non-Hispanic White, non-Hispanic Black, or Mexican American. National Health and Nutrition Examination Survey (NHANES) 1988–1994 and 1999–2018, United States

Notes: MEC = Mobile Examination Center; ng/mL = nanograms per milliliter.

^c^Serum cotinine levels were available for NHANES III participants 4 years of age and older.

From 1988-1991 to 2017-2018, the prevalence of people who did not smoke and had serum cotinine levels 0.05-0.10 ng/mL generally decreased consistently among people in three racial and ethnic groups: Mexican-American, non-Hispanic Black, and non-Hispanic White. However, the prevalence increased moderately among Mexican American people from 2003-2004 to 2007-2008. Among the racial and ethnic groups during this time frame, the prevalence was consistently highest among non-Hispanic Black people. Figure note “c” offers more details about the dataset for 1988-1991 and 1991-1994.

Source: NHANES, National Center for Health Statistics, public use data, 1988–2018.

### Exposure to Secondhand Tobacco Smoke by Age and Level of Income

Disparities in exposure to secondhand tobacco smoke persisted by poverty level from 1988 to 2018 (Table 2.45 and Figure 2.21). According to NHANES data, the magnitude of the decline in exposure to secondhand tobacco smoke, assessed using serum cotinine levels, was greater among people who lived at or above the poverty level and did not smoke (from 86.6% during 1988–1991 to 21.4% during 2017–2018) than it was among their counterparts who lived below the poverty level and did not smoke (from 91.4% during 1988–1991 to 44.9% during 2017–2018). Relative to people who lived at or above the poverty level, exposure to secondhand tobacco smoke was more than two times higher among people who lived below the poverty level during 2017–2018.

#### Children

During 2013–2014, an estimated 14 million children 3–11 years of age in the United States were exposed to secondhand tobacco smoke (Tsai et al. 2018). Compared with adults, children are at an elevated risk of exposure to secondhand tobacco smoke because of their increased intake of air relative to their body weights (Tonkin et al. 2009). According to data for 2000 and 2010 from the NHIS, exposure to secondhand tobacco smoke in the home declined over 10 years from 24.7% in 2000 to 8.2% in 2010 among youth less than 18 years of age (as reported by a knowledgeable adult in the household, usually a parent) and from 12.1% in 2000 to 4.4% in 2010 among adults (Yao et al. 2016). In 2010, no differences were found, overall, between youth whose parents had a high level of educational attainment (some college or higher) and those whose parents did not have a high level of educational attainment (high school graduate or less); and no differences were observed, overall, between youth or adults with a high level of family income and those with lower levels (middle or low) of family income. In 2010, levels of exposure to secondhand tobacco smoke were higher among youth in the Midwest and the South than they were among youth in other regions of the United States.

Table 2.47 Prevalence of self-reported exposure to secondhand tobacco smoke during the past 7 days^a^ among people who did not smoke,^b^ by age group, race and Hispanic origin, and indoor settings; National Health and Nutrition Examination Survey (NHANES) 2017–2018, United States

Age and race and Hispanic origin | Inside own household: % (95% CI) | At job: % (95% CI) | In a restaurant: % (95% CI) | In a bar: % (95% CI) | In a car: % (95% CI) | In other’s home: % (95% CI) | In other indoor area: % (95% CI) | Any of these indoor settings: % (95% CI)
Overall | 4.1 (2.7–6.2) | 6.3 (4.6–8.7) | 2.2 (1.6–3.0) | 3.1 (1.9–4.9) | 7.6 (5.9–9.8) | 3.8 (3.1–4.7) | 4.2 (2.9–6.0) | 19.2 (15.6–23.4)
Age group (in years)
3–19 | 6.9 (4.9–9.7) | —^c^ | —^c^ | —^c^ | 10.5 (8.0–13.7) | 4.2 (2.8–6.2) | 3.0 (1.9–4.8) | 18.2 (14.5–22.5)
≥20 | 3.2 (2.0–5.2) | 6.4 (4.6–8.8) | 2.5 (1.7–3.6) | 3.1 (1.9–5.0) | 6.7 (5.2–8.7) | 3.7 (2.9–4.7) | 4.6 (3.1–6.6) | 19.5 (15.6–24.1)
Race and Hispanic origin^d^
Non-Hispanic White | 3.8 (2.1–6.7) | 5.3 (3.5–8.2) | —^c^ | —^c^ | 7.5 (5.3–10.4) | 3.9 (2.9–5.3) | 4.5 (2.9–6.8) | 17.8 (13.7–22.9)
Non-Hispanic Black | 8.1 (6.0–10.8) | 4.6 (2.9–7.2) | —^c^ | —^c^ | 10.8 (9.0–12.9) | 6.8 (5.1–9.1) | 4.7 (3.3–6.7) | 25.9 (21.7–30.5)
Mexican American | 4.4 (2.4–7.8) | 12.1 (9.3–15.5) | —^c^ | —^c^ | 6.1 (4.2–8.7) | 3.0 (2.0–4.5) | —^c^ | 19.2 (16.1–22.8)

Source: NHANES, National Center for Health Statistics, public use data, 2017–2018.

Notes:CI = confidence interval; MEC = Mobile Examination Center; ng/mL = nanograms per milliliter.

a Self-reported exposure to secondhand tobacco smoke inside one’s own home was assessed by the question, “During the past 7 days … on how many days did (anyone who lives here) smoke tobacco inside this home?” Exposure to secondhand tobacco smoke at a job was assessed among people, 12 years of age and older, who reported working at a job or business outside of the home. For each site (restaurant, bar, car, in other’s home, in other indoor area, at a job), self-reported exposure to secondhand tobacco smoke was assessed among respondents who indicated they had spent time in that location during the past 7 days. Exposure in “any of these indoor settings” is a calculated variable and indicative of self-reported exposure to secondhand tobacco smoke in one or more indoor settings.

b People who did not smoke were defined by specific age groups as follows: children 3–11 years of age with serum cotinine ≤10 ng/mL; adolescents 12–19 years of age with serum cotinine ≤10 ng/mL and who did not report smoking during the past 30 days or using any nicotine-containing products during the past 5 days at the MEC interview; and adults 20 years of age and older with serum cotinine ≤10 ng/mL and who did not report currently smoking or using any nicotine-containing products during the past 5 days at MEC interview.

c Unstable estimate is not presented because of a small sample size and relative standard error >0.3.

d Data were limited to the three racial and Hispanic origin groups available: people who were non-Hispanic White, non-Hispanic Black, and Mexican American.

Figure 2.21 Trends in the prevalence of people who did not smoke^a^ a People who did not smoke were defined by specific age groups as follows: children 3–11 years of age with serum cotinine ≤10 ng/mL; adolescents 12–19 years of age with serum cotinine ≤10 ng/mL and who did not report smoking during the past 30 days or using any nicotinecontaining products during the past 5 days at the MEC interview; and adults 20 years of age and older with serum cotinine ≤10 ng/mL and who did not report currently smoking or using any nicotine-containing products during the past 5 days at the MEC interview. and had serum cotinine levels 0.05–0.10 ng/mL, by poverty status; National Health and Nutrition Examination Survey (NHANES) 1988–1994 and 1999–2018, United States

Notes:MEC = Mobile Examination Center; ng/mL = nanograms per milliliter.

^b^Serum cotinine levels were available for NHANES III participants 4 years of age and older.

^c^Income-to-poverty ratio <1.0.

From 1988-1991 to 2017-2018, the prevalence of people who did not smoke and had serum cotinine levels 0.05-0.10 ng/mL generally decreased consistently among people in three poverty status groups: below the poverty level, at or above the poverty level, and unspecified poverty level. However, moderate increases in prevalence occurred among people living (a) below the poverty level in 2003-2004, in 2013-2014, and in 20217-2018; (b) at or above the poverty level in 2003-2004; and (c) at an unspecified poverty level in 2003-2004 and in 2015-2016. Throughout the time frame, the prevalence was consistently highest among people living below the poverty level, followed by those living at an unspecified poverty level, and then by those living at or above the poverty level. Figure note “b” offers more details about the datasets for 1988-1991 and 1991-1994, and figure note “c” offers more details about those living below the poverty level.

Source: NHANES, National Center for Health Statistics, public use data, 1988–2018.

#### Adults

In terms of education level among adults 25 years of age and older, lesser declines in exposure to secondhand tobacco smoke were observed during the period from 1988–1991 to 2017–2018 among people who did not smoke who had achieved lower levels of educational attainment (Table 2.45 and Figure 2.22). According to 2017–2018 NHANES data, exposure to secondhand tobacco smoke was similar among people who did not smoke and had achieved less than a high school education (26.8%), a high school diploma or equivalent (24.9%), or some college or an associate degree (24.3%). However, exposure to secondhand tobacco smoke was significantly lower among people who did not smoke and had a college diploma or higher level of educational attainment (11.1%) compared with people who did not smoke who achieved lower levels of educational attainment (Table 2.45).

### Exposure to Secondhand Tobacco Smoke By Sexual Orientation

There is some evidence of disparities in exposure to secondhand tobacco by sexual orientation. For example, Cochran and colleagues (2013), using 2003–2010 NHANES data, found that exposure to secondhand tobacco smoke—as indicated by serum cotinine levels greater than or equal to 0.05 ng/mL—differed by sexual orientation among women 20–59 years of age. Specifically, exposure to secondhand tobacco smoke was higher among non-smoking women who identified as lesbian (56.2%) or who reported a lifetime experience with a same-gender partner (in absence of identifying as gay, lesbian, or bisexual) (47.7%) than among those who identified as exclusively hetero-sexual (33.0%; p<0.001). Among men, no significant difference in exposure to secondhand tobacco smoke by sexual orientation was observed.

Figure 2.22 Trends in the prevalence of adults, 25 years of age and older, who did not smoke^a^ a Adults who did not smoke were defined as people who had serum cotinine ≤10 ng/mL and who did not report currently smoking or using any nicotine-containing products during the past 5 days at the MEC interview. and had serum cotinine levels 0.05–0.10 ng/mL, by level of educational attainment; National Health and Nutrition Examination Survey (NHANES) 1988–1994 and 1999–2018, United States

Notes: MEC = Mobile Examination Center; ng/mL = nanograms per milliliter.

From 1988-1991 to 2017-2018, the prevalence of adults who did not smoke and had serum cotinine levels 0.05-0.10 ng/mL generally decreased consistently through 2011-2012 before flattening through 2017-2018 by four levels of educational attainment: Grade 11 or lower, high school diploma or equivalent, some college or associate degree, or at least a college diploma. Throughout the time frame, the prevalence was consistently highest among people with a high school diploma or equivalent or lower and lowest among those with at least a college diploma.

Source: NHANES, National Center for Health Statistics, public use data, 1988–2018.

Compared with women who identified as exclusively heterosexual, bisexual women were significantly more likely to self-report exposure to secondhand tobacco smoke at home (aOR = 3.96; 95% CI, 1.67–9.39) and at home or at work (aOR = 2.11; 95% CI, 1.12–3.97) (Cochran et al. 2013). Employed women who identified as lesbian were more likely to self-report exposure to secondhand tobacco smoke in the workplace (aOR = 2.96; 95% CI, 1.22–7.21) and employed men who identified as gay were less likely to report exposure to secondhand tobacco smoke in the workplace (aOR = 0.16; 95% CI, 0.03–0.91) than were their counterparts who identified as exclusively heterosexual (Cochran et al. 2013). In contrast, King and colleagues (2014a), using data from the 2009–2010 National Adult Tobacco Survey, reported no significant difference in the prevalence of self-reported exposure to secondhand smoke in the workplace among non-smoking adults who identified as lesbian, gay, bisexual, transgender (LGBT) (25.7%; 95% CI, 20.4–31.7) or among those who identified as heterosexual (20.2%; 95% CI, 19.4–21.1).

Max and colleagues (2016) assessed, from the 2003–2012 California Health Interview Survey, differences in self-reported exposure to secondhand tobacco smoke (on 1 or more days per week) in the homes of non-smoking adults, 18–70 years of age, in California by sexual orientation. Lesbian or bisexual women (aOR = 1.72; 95% CI, 1.19–2.49) and gay or bisexual men (aOR = 2.35; 95% CI, 1.72–3.21) were significantly more likely than women and men who identified as heterosexual, respectively, to report exposure to secondhand tobacco smoke in their homes. In time trend analyses, the decline in the odds of exposure to secondhand tobacco smoke in the home was larger among gay or bisexual men (11% per year) than it was among heterosexual men (6% per year). Similar declines were observed among heterosexual and lesbian or bisexual women, with adjusted odds declining by an average of 10% each year in both population groups. Despite these declines, exposure to secondhand tobacco smoke in the home remained higher among gay, lesbian, and bisexual men and women than among heterosexual men and women from 2003 to 2012 (Max et al. 2016).

## Summary of the Evidence and Implications

The 1998 Surgeon General’s report concluded that “[t]obacco use varies within and among racial/ethnic groups; among adults, American Indians and Alaska Natives have the highest prevalence of tobacco use, and African American and Southeast Asian men also have a high prevalence of smoking. Asian American and Hispanic women have the lowest prevalence” (USDHHS 1998, p. 6). Importantly, all of these populations have made considerable progress in lowering the prevalence of cigarette smoking since the 1998 report; from 1994–1995 to 2018, the prevalence of current cigarette smoking declined by 13.4 percentage points among American Indian and Alaska Native people (from 36.0% to 22.6%), by 11.9 percentage points among Black people (from 26.5% to 14.6%), by 11.4 percentage points among White people (from 26.4% to 15.0%), by 8.2 percentage points among Hispanic people (from 18.0% to 9.8%), and by 7.1 percentage points among Asian American and Pacific Islander people (from 14.2% to 7.1%) (USDHHS 1998).

Many of the disparities in tobacco use described in the 1998 report persist. For example, American Indian and Alaska Native people and Black men continue to have a higher prevalence of cigarette smoking, while Asian and Hispanic women continue to have a lower prevalence of cigarette smoking (Tables 2.2 and 2.7). Notably, the scope of the current report has expanded beyond the four racial and ethnic groups described in the 1998 report by analyzing tobacco use patterns among additional categories of race and ethnicity, as well as by sexual orientation and gender identity, occupation, and geographic setting; those at various levels of SES and educational attainment; and those with various mental health conditions or substance use disorders.

Despite much progress in reducing overall tobacco use over time, an estimated 47.1 million adults were current users of a tobacco product in 2020, 30.8 million of whom smoked cigarettes, 8.6 million smoked cigars, 5.7 million used smokeless tobacco, and 9.1 million used e-cigarettes (Cornelius et al. 2022). This chapter documents some of the uneven progress, key patterns, and trends in tobacco product use and exposure to secondhand tobacco smoke among several population groups in the United States. Continued action should be taken to address the disparities described in this chapter, including the implementation of comprehensive tobacco prevention and control programs and policies that address the diverse array of tobacco and nicotine products. Recent gains in measurement have allowed for understanding patterns of tobacco use among some population groups, but surveillance and intervention research data remain limited for many groups known to be at high risk for tobacco use, exposure to secondhand tobacco smoke, and targeted marketing. Further efforts are warranted to assess structural and social determinants of health across the lifespan, disaggregate data, and oversample disparate populations. Actions should go beyond estimating population-level results to include examinations of the effects of strategies for reducing disparities and advancing health equity (Rose et al. 2020).

## Conclusions

1. Racial and ethnic disparities in cigarette smoking have persisted since 2000, with prevalence remaining highest among American Indian and Alaska Native adults. Frequency, type, and amount of tobacco use; long-term cessation success; and patterns of use across the life course also differ by race and ethnicity. Within aggregate racial and ethnic groupings, disparities in tobacco use vary by ethnic group, nativity, and acculturation in the United States.
2. Disparities in cigarette smoking by educational attainment have widened in the past 50 years; the prevalence of smoking is substantially higher among people without college diplomas than it is among those with college diplomas.
3. The prevalence of tobacco use is higher among adults living in poverty than it is among adults living at or above the poverty level. Disparities in cigarette smoking by poverty status have persisted over four decades, and these differences remain when looking at the prevalence of smoking by poverty status and other demographic characteristics, including sex, race, ethnicity, and sexual orientation.
4. The prevalence of tobacco use is higher overall among youth and adults who identify as gay, lesbian, and bisexual than it is among youth and adults who identify as heterosexual, but the prevalence of tobacco use varies by different populations, such as gay, lesbian, or bisexual populations, and by specific tobacco products. Increased availability and improvements in the measures to assess sexual orientation and gender identity in federal, state, and local surveillance systems will assist efforts to better address disparities among these populations.
5. The prevalence of ever and current smoking is higher among manual labor and service workers than it is among workers in other occupational groups. Conversely, the prevalence of cigarette smoking cessation is lower among manual labor and service workers than it is among workers in other occupational groups. Accommodation and food service, construction, and mining are the occupation groups with the highest prevalence of current cigarette smoking. These settings may warrant greater support for smoking cessation interventions.
6. The prevalence of tobacco use is generally higher in the South and Midwest than it is in other regions of the United States. Additionally, the prevalence of cigarette and smokeless tobacco use is higher among people living in rural areas than it is among people living in urban areas.
7. People living with any mental health condition or substance use disorder are at increased risk of tobacco use. The intersection of mental health, substance use, and sociodemographic characteristics—such as age, sex, race and ethnicity, sexual orientation, and socioeconomic status—adds to the risk of tobacco use.
8. Despite progress in the adoption of smokefree policies, the prevalence of exposure to secondhand tobacco smoke remains disproportionately high among (a) children compared with adults, (b) non-smoking African American youth and adults compared with non-smoking White or Mexican American youth and adults, (c) families in lower income groups compared with families in higher income groups, and (d) adults without college diplomas compared with adults with college diplomas. The magnitude of these disparities has increased since 2000.

## References

Abuelezam NN, El-Sayed AM, Galea S, Gordon NP. Health risks and chronic health conditions among Arab American and White adults in Northern California. Ethnicity & Disease 2021;31(2):235–42.33883864
Agaku IT, Odani S, King BA, Armour BS. Prevalence and correlates of secondhand smoke exposure in the home and in a vehicle among youth in the United States. Preventive Medicine 2019;126:105745.31175879
Alexander LA, Crawford T, Mendiondo MS. Occupational status, work-site cessation programs and policies and menthol smoking on quitting behaviors of U.S. smokers. Addiction 2010;105(Suppl 1):S95–S104.
American Nonsmokers’ Rights Foundation. Percent of U.S. State Populations Covered by 100% Smokefree Air Laws, January 1, 2023; <https://no-smoke.org/wp-content/uploads/pdf/percentstatepops.pdf>; accessed: December 13, 2023.
Arnett JJ, Brody GH. A fraught passage: the identity challenges of African American emerging adulthood. Human Development 2008;51:291–3.
Asfar T, Arheart KL, Dietz NA, Caban-Martinez AJ, Fleming LE, Lee DJ. Changes in cigarette smoking behavior among U.S. young workers from 2005 to 2010: the role of occupation. Nicotine & Tobacco Research 2016;18(6):1414–23.26508398
Azagba S, Shan L. Heated tobacco products: awareness and ever use among U.S. adults. American Journal of Preventive Medicine 2021;60(5):684–91.33518430
Babb S, Malarcher A, Asman K, Johns M, Caraballo R, VanFrank B, Garrett B. Disparities in cessation behaviors between Hispanic and non-Hispanic White adult cigarette smokers in the United States, 2000–2015. Preventing Chronic Disease 2020;17:E10.31999539
Backinger CL, Fagan P, O’Connell ME, Grana R, Lawrence D, Bishop JA, Gibson JT. Use of other tobacco products among U.S. adult cigarette smokers: prevalence, trends and correlates. Addictive Behaviors 2008;33(3):472–89.18053653
Barbeau EM, Krieger N, Soobader MJ. Working class matters: socioeconomic disadvantage, race/ethnicity, gender, and smoking in NHIS 2000. American Journal of Public Health 2004;94(2):269–78.14759942
Benowitz NL, Schultz KE, Haller CA, Wu AH, Dains KM, Jacob P 3rd. Prevalence of smoking assessed biochemically in an urban public hospital: a rationale for routine cotinine screening. American Journal of Epidemiology 2009;170(7):885–91.19713287
Binswanger IA, Krueger PM, Steiner JF. Prevalence of chronic medical conditions among jail and prison inmates in the U.S.A. compared with the general population. Journal of Epidemiology and Community Health 2009;63(11):912–9.19648129
Blanco L, Garcia R, Pérez-Stable EJ, White MM, Messer K, Pierce JP, Trinidad DR. National trends in smoking behaviors among Mexican, Puerto Rican, and Cuban men and women in the United States. American Journal of Public Health 2014;104(5):896–903.24625159
Brener ND, Billy JO, Grady WR. Assessment of factors affecting the validity of self-reported healthrisk behavior among adolescents: evidence from the scientific literature. Journal of Adolescent Health 2003;33(6):436–57.
Brown-Johnson CG, Cataldo JK, Orozco N, Lisha NE, Hickman NJ 3rd, Prochaska JJ. Validity and reliability of the Internalized Stigma of Smoking Inventory: an exploration of shame, isolation, and discrimination in smokers with mental health diagnoses. American Journal on Addictions 2015;24(5):410–8.25930661
Buchting FO, Emory KT, Scout, Kim Y, Fagan P, Vera LE, Emery S. Transgender use of cigarettes, cigars, and e-cigarettes in a national study. American Journal of Preventive Medicine 2017;53(1):e1–e7.28094133
Budiman A. Key findings about U.S. immigrants, August 20, 2020; <https://www.pewresearch.org/fact-tank/2020/08/20/key-findings-about-u-s-immigrants/>; accessed: October 6, 2021.
Cao P, Jeon J, Tam J, Fleischer NL, Levy DT, Holford TR, Meza R. Smoking disparities by level of educational attainment and birth cohort in the U.S. American Journal of Preventive Medicine 2023;64(4 Suppl 1): S22–S31.36935129
Cao P, Jeon J, Tam J, Holford TR, Fleischer NL, Meza R. Smoking disparities by level of educational attainment in the United States, 1966 to 2015. Tobacco Induced Diseases 2018;16(Suppl 1):899.
Capehart T. Trends in U.S. Tobacco Farming. Washington (DC): U.S. Department of Agriculture, Economic Research Service, November 2004. Publication No. TBS-257-02.
Caraballo RS, Sharapova SR, Asman KJ. Does a racegender-age crossover effect exist in current cigarette smoking between non-Hispanic Blacks and non-Hispanic Whites? United States, 2001–2013. Nicotine & Tobacco Research 2016;18(Suppl 1):S41–S48.26980863
Caraballo RS, Yee SL, Gfroerer JC, Pechacek TF, Henson R. Tobacco use among racial and ethnic population subgroups of adolescents in the United States. Preventing Chronic Disease 2006;3(2):A39.16539780
Centers for Disease Control and Prevention. Second National Report on Human Exposure to Environmental Chemicals. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Environmental Health, 2003. NCEH Publication No 02-0716.
Centers for Disease Control and Prevention. Third National Report on Human Exposure to Environmental Chemicals. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Environmental Health, 2005. NCEH Publication No 05-0570.
Centers for Disease Control and Prevention. Vital signs: nonsmokers’ exposure to secondhand smoke—United States, 1999–2008. Morbidity and Mortality Weekly Report 2010;59(35):1141–6.20829748
Centers for Disease Control and Prevention. Identifying and Eliminating Tobacco-Related Disparities: Key Outcome Indicators for Evaluating Comprehensive Tobacco Control Programs—2022. Atlanta (GA): Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2022; <https://www.cdc.gov/tobacco/stateandcommunity/guides/pdfs/2022-KOI-Guide-508.pdf>; accessed: May 30, 2023.
Centers for Disease Control and Prevention. 2023 National Health Interview Survey (NHIS) Questionnaire, 2023a; <https://ftp.cdc.gov/pub/Health_Statistics/NCHS/Survey_Questionnaires/NHIS/2023/EnglishQuest-508.pdf>; accessed: August 25, 2023.
Centers for Disease Control and Prevention. STATE System smokefree indoor air fact sheet, January 27, 2023b; <https://www.cdc.gov/statesystem/factsheets/sfia/SmokeFreeIndoorAir.html>; accessed: June 23, 2023.
Centers for Disease Control and Prevention. STATE System vehicles fact sheet, January 27, 2023c; <https://www.cdc.gov/statesystem/factsheets/vehicles/Vehicles.html>; accessed: June 22, 2023.
Centers for Disease Control and Prevention. 1991–2019 high school Youth Risk Behavior Survey data, n.d.a; <http://nccd.cdc.gov/youthonline/>; accessed: September 24, 2020.
Centers for Disease Control and Prevention. High school students who currently smoked cigarettes daily, 2019, n.d.b; <https://yrbs-explorer.services.cdc.gov/#/tables?questionCode=QNDAYCIG&topicCode=C02&year=2019>; accessed: November 1, 2022.
Centers for Disease Control and Prevention. High school students who currently smoked cigarettes frequently, 2019, n.d.c; <https://yrbs-explorer.services.cdc.gov/#/tables?questionCode=QNFRCIG&topicCode=C02&year=2019>; accessed: November 1, 2022.
Centers for Disease Control and Prevention. High school students who currently smoked cigars daily, 2019, n.d.d; <https://yrbs-explorer.services.cdc.gov/#/tables?questionCode=QNDAYCGR&topicCode=C02&year=2019>; accessed: November 1, 2022.
Centers for Disease Control and Prevention. High school students who currently smoked cigars frequently, 2019, n.d.e; <https://yrbs-explorer.services.cdc.gov/#/tables?questionCode=QNFRCGR&topicCode=C02&year=2019>; accessed: November 1, 2022.
Centers for Disease Control and Prevention. High school students who currently used electronic vapor products daily, 2019, n.d.f; <https://yrbs-explorer.services.cdc.gov/#/tables?questionCode=QNDAYEVP&topicCode=C02&year=2019>; accessed: November 1, 2022.
Centers for Disease Control and Prevention. High school students who currently used electronic vapor products frequently, 2019, n.d.g; <https://yrbs-explorer.services.cdc.gov/#/tables?questionCode=QNFREVP&topicCode=C02&year=2019>; accessed: November 1, 2022.
Centers for Disease Control and Prevention. High school students who first tried cigarette smoking before age 13 years, 2019, n.d.h; <https://yrbs-explorer.services.cdc.gov/#/tables?questionCode=H31&topicCode=C02&year=2019>; accessed: November 1, 2022. Centers for Disease Control and Prevention. National Youth Tobacco Survey (NYTS), n.d.i; <https://www.cdc.gov/tobacco/data_statistics/surveys/nyts/index.htm>; accessed: March 1, 2022.
Centers for Disease Control and Prevention. State Tobacco Activities Tracking and Evaluation (STATE) System, n.d.j; <https://www.cdc.gov/statesystem/index.html>; accessed: May 30, 2019.
Cepeda-Benito A, Doogan NJ, Redner R, Roberts ME, Kurti AN, Villanti AC, Lopez AA, Quisenberry AJ, Stanton CA, Gaalema DE, . Trend differences in men and women in rural and urban U.S. settings. Preventive Medicine 2018;117:69–75.29627511
Chae DH, Gavin AR, Takeuchi DT. Smoking prevalence among Asian Americans: findings from the National Latino and Asian American Study (NLAAS). Public Health Reports 2006;121(6):755–63.17278411
Chang E, Dove M, Saw A, Tsoh JY, Fung LC, Tong EK. Home smoking bans and urinary NNAL levels to measure tobacco exposure in Chinese American household pairs. International Journal of Environmental Research and Public Health 2021;18(14):7682.34300133
Chen P, Jacobson KC. Developmental trajectories of substance use from early adolescence to young adulthood: gender and racial/ethnic differences. Journal of Adolescent Health 2012;50(2):154–63.
Cochran SD, Bandiera FC, Mays VM. Sexual orientationrelated differences in tobacco use and secondhand smoke exposure among U.S. adults aged 20 to 59 years: 2003–2010 National Health and Nutrition Examination Surveys. American Journal of Public Health 2013;103(10):1837–44.23948019
Cohn A, Elmasry H, Niaura R. Facility-level, state, and financial factors associated with changes in the provision of smoking cessation services in U.S. substance abuse treatment facilities: results from the National Survey of Substance Abuse Treatment Services 2006 to 2012. Journal of Substance Abuse Treatment 2017;77:107–14.28476262
Cokkinides VE, Halpern MT, Barbeau EM, Ward E, Thun MJ. Racial and ethnic disparities in smokingcessation interventions: analysis of the 2005 National Health Interview Survey. American Journal of Preventive Medicine 2008;34(5):404–12.18407007
Cole ER. Intersectionality and research in psychology. American Psychologist 2009;64(3):170–80.19348518
Conway KP, Green VR, Kasza KA, Silveira ML, Borek N, Kimmel HL, Sargent JD, Stanton C, Lambert E, Hilmi N, . Co-occurrence of tobacco product use, substance use, and mental health problems among adults: findings from Wave 1 (2013–2014) of the Population Assessment of Tobacco and Health (PATH) Study. Drug and Alcohol Dependence 2017;177:104–11.28582698
Conway KP, Green VR, Kasza KA, Silveira ML, Borek N, Kimmel HL, Sargent JD, Stanton CA, Lambert E, Hilmi N, . Co-occurrence of tobacco product use, substance use, and mental health problems among youth: findings from Wave 1 (2013–2014) of the Population Assessment of Tobacco and Health (PATH) Study. Addictive Behaviors 2018;76:208–17.28846942
Cook BL, Wayne GF, Kafali EN, Liu Z, Shu C, Flores M. Trends in smoking among adults with mental illness and association between mental health treatment and smoking cessation. JAMA: the Journal of the American Medical Association 2014;311(2):172–82.24399556
Cornelius ME, Loretan CG, Wang TW, Jamal A, Homa DM. Tobacco product use among adults—United States, 2020. Morbidity and Mortality Weekly Report 2022;71(11):397–405.35298455
Cornelius ME, Wang TW, Jamal A, Loretan CG, Neff LJ. Tobacco product use among adults—United States, 2019. Morbidity and Mortality Weekly Report 2020;69(46):1736–42.33211681
Coughlin LN, Bonar EE, Bohnert KM, Jannausch M, Walton MA, Blow FC, Ilgen MA. Changes in urban and rural cigarette smoking and cannabis use from 2007 to 2017 in adults in the United States. Drug and Alcohol Dependence 2019;205:107699.31707265
Coulter RWS, Ware D, Fish JN, Plankey MW. Latent classes of polysubstance use among adolescents in the United States: intersections of sexual identity with sex, age, and race/ethnicity. LGBT Health 2019;6(3):116–25.30822259
Cubbin C, Soobader MJ, LeClere FB. The intersection of gender and race/ethnicity in smoking behaviors among menthol and non-menthol smokers in the United States. Addiction 2010;105(Suppl 1):32–8.21059134
Cummins SE, Zhu S-H, Tedeschi GJ, Gamst AC, Myers MG. Use of e-cigarettes by individuals with mental health conditions. Tobacco Control 2014;23(Suppl 3):iii48–iii53.24824516
Delnevo CD, Bover-Manderski MT, Hrywna M. Cigar, marijuana, and blunt use among U.S. adolescents: are we accurately estimating the prevalence of cigar smoking among youth? Preventive Medicine 2011a;52(6):475–6.21443900
Delnevo CD, Giovenco DP, Steinberg MB, Villanti AC, Pearson JL, Niaura RS, Abrams DB. Patterns of electronic cigarette use among adults in the United States. Nicotine & Tobacco Research 2016;18(5):715–9.26525063
Delnevo CD, Gundersen DA, Hrywna M, Echeverria SE, Steinberg MB. Smoking-cessation prevalence among U.S. smokers of menthol versus non-menthol cigarettes. American Journal of Preventive Medicine 2011b;41(4):357–65.21961462
Dermody SS. Risk of polysubstance use among sexual minority and heterosexual youth. Drug and Alcohol Dependence 2018;192:38–44.30205306
Dermody SS, Heffner JL, Hinds JT, McQuoid J, Quisenberry AJ, Tan ASL, Vogel EA. We’re in this together: promoting health equity, diversity, and inclusion in tobacco research for sexual and gender minority populations. Nicotine & Tobacco Research 2020;22(12):2276–9.32335682
Dobalian A, Rivers PA. Racial and ethnic disparities in the use of mental health services. Journal of Behavioral Health Services and Research 2008;35(2):128–41.18074230
Dominguez K, Penman-Aguilar A, Chang MH, Moonesinghe R, Castellanos T, Rodriguez-Lainz A, Schieber R. Vital signs: leading causes of death, prevalence of diseases and risk factors, and use of health services among Hispanics in the United States—2009–2013. Morbidity and Mortality Weekly Report 2015;64(17):469–78.25950254
Doogan NJ, Roberts ME, Wewers ME, Stanton CA, Keith DR, Gaalema DE, Kurti AN, Redner R, CepedaBenito A, Bunn JY, . A growing geographic disparity: rural and urban cigarette smoking trends in the United States. Preventive Medicine 2017;104:79–85.28315761
Eichner JE, Wang W, Zhang Y, Lee ET, Welty TK. Tobacco use and cardiovascular disease among American Indians: the Strong Heart Study. International Journal of Environmental Research and Public Health 2010;7(10):3816–30.21139862
Epperson AE, Gonzalez M, Skorek M, Song AV. Challenging assumptions about race/ethnicity, socioeconomic status, and cigarette smoking among adolescents. Journal of Racial and Ethnic Health Disparities 2022;9(2):436–43.33543446
Fagan P, Shavers VL, Lawrence D, Gibson JT, O’Connell ME. Employment characteristics and socioeconomic factors associated with disparities in smoking abstinence and former smoking among U.S. workers. Journal of Health Care for the Poor and Underserved 2007;18(4 Suppl):52–72.
Falk DE, Yi HY, Hiller-Sturmhöfel S. An epidemiologic analysis of co-occurring alcohol and tobacco use and disorders: findings from the National Epidemiologic Survey on Alcohol and Related Conditions. Alcohol Research & Health 2006;29(3):162–71.17373404
Fallin A, Glantz SA. Tobacco-control policies in tobaccogrowing states: where tobacco was king. Milbank Quarterly 2015;93(2):319–58.26044632
Federal Bureau of Prisons. Program Statement No. 1640.05. Smoking/No Smoking Areas, January 7, 2015; <https://www.bop.gov/policy/progstat/1640_005.pdf>; accessed: June 23, 2023.
Federal Interagency Working Group on Improving Measurement of Sexual Orientation and Gender Identity in Federal Surveys. Toward a Research Agenda for Measuring Sexual Orientation and Gender Identity in Federal Surveys: Findings, Recommendations, and Next Steps, October 20, 2016; <https://nces.ed.gov/FCSM/pdf/SOGI_Research_Agenda_Final_Report_20161020.pdf>; accessed: August 25, 2023.
Federal Register. Executive Office of the President, Office of Management and Budget, Office of Information and Regulatory Affairs. Revisions to the standards for the classification of federal data on race and ethnicity, 62 Fed. Reg. 210 (1997).
Federal Register. U.S. Department of Health and Human Services, Food and Drug Administration. Tobacco product standard for menthol in cigarettes, proposed rule (21 CFR Part 1162), 87 Fed. Reg. 26454 (2022).
Federal Register, Office of the Assistant Secretary for Public and Indian Housing, U.S. Department of Housing and Urban Development. Instituting smoke-free public housing; final rule (24 CFR Parts 956 and 966), 81 Fed. Reg. 87430 (2016), <https://www.federalregister.gov/documents/2016/12/05/2016-28986/instituting-smoke-free-public-housing>; accessed: May 20, 2021.
Friis RH, Forouzesh M, Chhim HS, Monga S, Sze D. Sociocultural determinants of tobacco use among Cambodian Americans. Health Education Research 2006;21(3):355–65.16740680
Gambino C. Random samplings: immigrant families and educational attainment, March 2017; <https://www.census.gov/newsroom/blogs/random-samplings/2017/03/immigrant_familiesa.html>; accessed: September 21, 2023.
Gentzke AS, Creamer M, Cullen KA, Ambrose BK, Willis G, Jamal A, King BA. Vital signs: tobacco product use among middle and high school students—United States, 2011–2018. Morbidity and Mortality Weekly Report 2019;68:157–64.30763302
Gentzke AS, Wang TW, Cornelius M, Park-Lee E, Ren C, Sawdey MD, Cullen KA, Loretan C, Jamal A, Homa DM. Tobacco product use and associated factors among middle and high school students—National Youth Tobacco Survey, United States, 2021. Morbidity and Mortality Weekly Report Surveillance Summaries 2022;71(5):1–29.
Gentzke AS, Wang TW, Jamal A, Park-Lee E, Ren C, Cullen KA, Neff L. Tobacco product use among middle and high school students—United States, 2020. Morbidity and Mortality Weekly Report 2020;69(50):1881–8.33332300
Geronimus AT, Neidert LJ, Bound J. Age patterns of smoking in U.S. black and white women of childbearing age. American Journal of Public Health 1993;83(9):1258–64.8363001
Giovino GA, Gardiner PS. Understanding tobacco use behaviors among African Americans: progress, critical gaps, and opportunities. Nicotine & Tobacco Research 2016;18(Suppl 1):S1–S6.26980859
Giovino GA, Villanti AC, Mowery PD, Sevilimedu V, Niaura RS, Vallone DM, Abrams DB. Differential trends in cigarette smoking in the U.S.A.: is menthol slowing progress? Tobacco Control 2015;24(1):28–37.23997070
Gonzalez M, Sanders-Jackson A, Song AV, Cheng KW, Glantz SA. Strong smoke-free law coverage in the United States by race/ethnicity: 2000–2009. American Journal of Public Health 2013;103(5):e62–e66.23488507
Gorman BK, Lariscy JT, Kaushik C. Gender, acculturation, and smoking behavior among U.S. Asian and Latino immigrants. Social Science & Medicine 2014;106:110–8.24561772
Green VR, Conway KP, Silveira ML, Kasza KA, Cohn A, Cummings KM, Stanton CA, Callahan-Lyon P, Slavit W, Sargent JD, . Mental health problems and onset of tobacco use among 12- to 24-year-olds in the PATH Study. Journal of the American Academy of Child and Adolescent Psychiatry 2018;57(12):944–54.30522740
Gundersen DA, Delnevo CD, Wackowski O. Exploring the relationship between race/ethnicity, menthol smoking, and cessation, in a nationally representative sample of adults. Preventive Medicine 2009;49(6):553–7.19850064
Gundersen DA, Echeverria SE, Lewis MJ, Giovino GA, Ohman-Strickland P, Delnevo CD. Heterogeneity in past year cigarette smoking quit attempts among Latinos. Journal of Environmental and Public Health 2012:378165.
Hafez AY, Gonzalez M, Kulik MC, Vijayaraghavan M, Glantz SA. Uneven access to smoke-free laws and policies and its effect on health equity in the United States: 2000–2019. American Journal of Public Health 2019;109(11):1568–75.31536405
Ham DC, Przybeck T, Strickland JR, Luke DA, Bierut LJ, Evanoff BA. Occupation and workplace policies predict smoking behaviors: analysis of national data from the Current Population Survey. Journal of Occupational and Environmental Medicine 2011;53(11):1337–45.21988795
Harper S, Lynch J. Methods for Measuring Cancer Disparities: Using Data Relevant to Healthy People 2010 Cancer-Related Objectives. Bethesda (MD): National Cancer Institute, 2005. NIH Publication No. 05-5777.
Hennrikus DJ, Jeffery RW, Lando HA. Occasional smoking in a Minnesota working population. American Journal of Public Health 1996;86(9):1260–6.8806378
Ho JY, Fenelon A. The contribution of smoking to educational gradients in U.S. life expectancy. Journal of Health and Social Behavior 2015;56(3):307–22.26199287
Inoue-Choi M, Christensen CH, Rostron BL, Cosgrove CM, Reyes-Guzman C, Apelberg B, Freedman ND. Dose-response association of low-intensity and non-daily smoking with mortality in the United States. JAMA Network Open 2020;3(6):e206436.32492162
Inoue-Choi M, McNeel TS, Hartge P, Caporaso NE, Graubard BI, Freedman ND. Non-daily cigarette smokers: mortality risks in the U.S. American Journal of Preventive Medicine 2019;56(1):27–37.30454906
James DJ, Glaze LE. Mental Health Problems of Prison and Jail Inmates. Washington (DC): U.S. Department of Justice, Office of Justice Programs, Bureau of Justice Statistics, 2006.
Johnson CC, Webber LS, Myers L, Boris NW, Berenson GS. Co-use of alcohol and tobacco among ninth-graders in Louisiana. Preventing Chronic Disease 2009;6(3):A85.19527586
Jones MR, Apelberg BJ, Tellez-Plaza M, Samet JM, Navas-Acien A. Menthol cigarettes, race/ethnicity, and biomarkers of tobacco use in U.S. adults: the 1999–2010 National Health and Nutrition Examination Survey (NHANES). Cancer Epidemiology, Biomarkers & Prevention 2013;22(2):224–32.
Kandel D, Schaffran C, Hu MC, Thomas Y. Age-related differences in cigarette smoking among whites and African-Americans: evidence for the crossover hypothesis. Drug and Alcohol Dependence 2011;118(2–3):280–7.21561724
Kann L, McManus T, Harris WA, Shanklin SL, Flint KH, Queen B, Lowry R, Chyen D, Whittle L, Thornton J, . Youth Risk Behavior Surveillance—United States, 2017. Morbidity and Mortality Weekly Report Surveillance Summaries 2018;67(8):1–114.
Kaplan RC, Bangdiwala SI, Barnhart JM, Castaneda SF, Gellman MD, Lee DJ, Perez-Stable EJ, Talavera GA, Youngblood ME, Giachello AL. Smoking among U.S. Hispanic/Latino adults: the Hispanic community health study/study of Latinos. American Journal of Preventive Medicine 2014;46(5):496–506.24745640
Kauffman RM, Ferketich AK, Wewers ME. Tobacco policy in American prisons, 2007. Tobacco Control 2008;17(5):357–60.18603604
Kayyali R. U.S. Census classifications and Arab Americans: contestations and definitions of identity markers. Journal of Ethnic and Migration Studies 2013;39(8):1299–318.
Kennedy SM, Davis SP, Thorne SL. Smoke-free policies in U.S. prisons and jails: a review of the literature. Nicotine & Tobacco Research 2015;17(6):629–35.25475088
Kennedy SM, Sharapova SR, Beasley DD, Hsia J. Cigarette smoking among inmates by race/ethnicity: impact of excluding African American young adult men from national prevalence estimates. Nicotine & Tobacco Research 2016;18(Suppl 1):S73–S78.26980867
Keyes KM, Vo T, Wall MM, Caetano R, Suglia SF, Martins SS, Galea S, Hasin D. Racial/ethnic differences in use of alcohol, tobacco, and marijuana: is there a cross-over from adolescence to adulthood? Social Science & Medicine 2015;124:132–41.25461870
Kim S, Selya A. Rural disparities in adolescent smoking prevalence. Journal of Rural Health 2021.
King BA, Babb SD, Tynan MA, Gerzoff RB. National and state estimates of secondhand smoke infiltration among U.S. multiunit housing residents. Nicotine & Tobacco Research 2013a;15(7):1316–21.23248030
King BA, Dube SR, Homa DM. Smoke-free rules and secondhand smoke exposure in homes and vehicles among U.S. adults, 2009–2010. Preventing Chronic Disease 2013b;10:E79.23680508
King BA, Homa DM, Dube SR, Babb SD. Exposure to secondhand smoke and attitudes toward smoke-free work-places among employed U.S. adults: findings from the National Adult Tobacco Survey. Nicotine & Tobacco Research 2014a;16(10):1307–18.24812025
King BA, Patel R, Babb SD. Prevalence of smokefree home rules—United States, 1992–1993 and 2010–2011. Morbidity and Mortality Weekly Report 2014b;63(35):765–9.25188494
Kruger J, Jama A, Kegler M, Baker Holmes C, Hu S, King B. Smoke-free rules and secondhand smoke exposure in vehicles among U.S. adults—National Adult Tobacco Survey, 2009–2010 and 2013–2014. International Journal of Environmental Research and Public Health 2016;13(11).
Kulak JA, Cornelius ME, Fong GT, Giovino GA. Differences in quit attempts and cigarette smoking abstinence between Whites and African Americans in the United States: literature review and results from the International Tobacco Control U.S. Survey. Nicotine & Tobacco Research 2016;(Suppl 1):S79–S87.
Lawrence D, Fagan P, Backinger CL, Gibson JT, Hartman A. Cigarette smoking patterns among young adults aged 18–24 years in the United States. Nicotine & Tobacco Research 2007;9(6):687–97.17558826
Lawrence D, Rose A, Fagan P, Moolchan ET, Gibson JT, Backinger CL. National patterns and correlates of mentholated cigarette use in the United States. Addiction 2010;105(Suppl 1):13–31.21059133
Lawrence EM, Pampel FC, Mollborn S. Life course transitions and racial and ethnic differences in smoking prevalence. Advances in Life Course Research 2014;22:27–40.26047689
Levy DT, Blackman K, Tauras J, Chaloupka FJ, Villanti AC, Niaura RS, Vallone DM, Abrams DB. Quit attempts and quit rates among menthol and nonmenthol smokers in the United States. American Journal of Public Health 2011;101(7):1241–7.21566032
Luczak SE, Khoddam R, Yu S, Wall TL, Schwartz A, Sussman S. Prevalence and co-occurrence of addictions in U.S. ethnic/racial groups: implications for genetic research. American Journal on Addictions 2017;26(5):424–36.27759944
Mantey DS, Onyinye ON, Montgomery L. Prevalence and correlates of daily blunt use among U.S. African American, Hispanic, and White adults from 2014 to 2018. Psychology of Addictive Behaviors 2021;35(5):514–22.33914562
Martell BN, Garrett BE, Caraballo RS. Disparities in adult cigarette smoking—United States, 2002–2005 and 2010–2013. Morbidity and Mortality Weekly Report 2016;65(30):753–8.27491017
Marynak K, VanFrank B, Tetlow S, Mahoney M, Phillips E, Jamal Mbbs A, Schecter A, Tipperman D, Babb S. Tobacco cessation interventions and smoke-free policies in mental health and substance abuse treatment facilities—United States, 2016. Morbidity and Mortality Weekly Report 2018;67(18):519–23.29746451
Marynak KL, Wang X, Borowiecki M, Kim Y, Tynan MA, Emery S, King BA. Nicotine pouch unit sales in the U.S., 2016–2020. JAMA: the Journal of the American Medical Association 2021;326(6):566–8.34374729
Max WB, Stark B, Sung HY, Offen N. Sexual identity disparities in smoking and secondhand smoke exposure in California: 2003–2013. American Journal of Public Health 2016;106(6):1136–42.26985597
Maziak W, Taleb ZB, Bahelah R, Islam F, Jaber R, Auf R, Salloum RG. The global epidemiology of waterpipe smoking. Tobacco Control 2015;24(Suppl 1):i3–i12.25298368
Mills SD, Hao Y, Ribisl KM, Wiesen CA, Hassmiller Lich K. The relationship between menthol cigarette use, smoking cessation, and relapse: findings from Waves 1 to 4 of the Population Assessment of Tobacco and Health Study. Nicotine & Tobacco Research 2021;23(6):966–75.33063826
Minton TD, Beatty LG, Zeng Z. Correctional Populations in the United States, 2019—Statistical Tables, July 2021; <https://bjs.ojp.gov/sites/g/files/xyckuh236/files/media/document/cpus19st.pdf>; accessed: November 1, 2022.
Montgomery L, Mantey D. Racial/ethnic differences in prevalence and correlates of blunt smoking among adolescents. Journal of Psychoactive Drugs 2018;50(3):195–205.29199906
Montgomery L, Mantey DS. Correlates of blunt smoking among African American, Hispanic/Latino, and white adults: results from the 2014 national survey on drug use and health. Substance Use & Misuse 2017;52(11):1449–59.28467153
Montgomery L, Mantey DS, Peters EN, Herrmann ES, Winhusen T. Blunt use and menthol cigarette smoking: an examination of adult marijuana users. Addictive Behaviors 2020;102:106153.31704435
Montgomery L, Oluwoye O. The truth about marijuana is all rolled up in a blunt: prevalence and predictors of blunt use among young African–American adults. Journal of Substance Use 2016;21(4):374–80.
Montgomery L, Ramo D. What did you expect?: The interaction between cigarette and blunt vs. non-blunt marijuana use among African American young adults. Journal of Substance Use 2017;22(6):612–6.29333104
Mukherjea A, Modayil MV, Tong EK. Moving toward a true depiction of tobacco behavior among Asian Indians in California: prevalence and factors associated with cultural smokeless tobacco product use. Cancer 2018;124(Suppl 7):1607–13.29578599
Mukherjea A, Wackowski OA, Lee YO, Delnevo CD. Asian American, Native Hawaiian and Pacific Islander tobacco use patterns. American Journal of Health Behavior 2014;38(3):362–9.24636032
Mumford EA, Stillman FA, Tanenbaum E, Doogan NJ, Roberts ME, Wewers ME, Chelluri D. Regional rural-urban differences in e-cigarette use and reasons for use in the United States. Journal of Rural Health 2019;35(3):395–404.
National Academies of Sciences, Engineering, and Medicine. Measuring Sex, Gender Identity, and Sexual Orientation. Washington (DC): The National Academies Press, 2022.
National Cancer Institute. A Socioecological Approach to Addressing Tobacco-Related Health Disparities. Tobacco Control Monograph 22. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2017. NIH Publication No. 17-CA-8035A.
National Center for Health Statistics. Data File Documentation, National Health Interview Survey, 2008. (Machine readable data file and documentation). Hyattsville (MD): National Center for Health Statistics, Centers for Disease Control and Prevention, June 2009.
National Center for Health Statistics. Survey Description, National Health Interview Survey, 2015. Hyattsville (MD): National Center for Health Statistics, Centers for Disease Control and Prevention, June 2016.
National Center for Health Statistics. 2022 NHIS: Survey implementation materials, 2022; <https://www.cdc.gov/nchs/nhis/2022nhis.htm>; accessed: June 23, 2023.
National Institutes of Health. Methods and measurement in sexual & gender minority health research, n.d.; <https://dpcpsi.nih.gov/sgmro/measurement-and-data>; accessed: November 12, 2020.
National Science and Technology Council. Federal Evidence Agenda on LGBTQI+ Equity. Washington (DC): Office of Science and Technology Policy, Executive Office of the President, January 2023.
Nelson DE, Mowery P, Asman K, Pederson LL, O’Malley PM, Malarcher A, Maibach EW, Pechacek TF. Long-term trends in adolescent and young adult smoking in the United States: metapatterns and implications. American Journal of Public Health 2008;98(5):905–15.18382001
Nez Henderson P, Jacobsen C, Beals J. Correlates of cigarette smoking among selected Southwest and Northern plains tribal groups: the AI-SUPERPFP Study. American Journal of Public Health 2005;95(5):867–72.15855467
Nighbor TD, Doogan NJ, Roberts ME, Cepeda-Benito A, Kurti AN, Priest JS, Johnson HK, Lopez AA, Stanton CA, Gaalema DE, . Smoking prevalence and trends among a U.S. national sample of women of reproductive age in rural versus urban settings. PLoS One 2018;13(11):e0207818.30485376
Noland M, Rayens MK, Wiggins AT, Huntington-Moskos L, Rayens EA, Howard T, Hahn EJ. Current use of e-cigarettes and conventional cigarettes among U.S. high school students in urban and rural locations: 2014 National Youth Tobacco Survey. American Journal of Health Promotion 2018;32(5):1239–47.28731384
Nonnemaker J, Hersey J, Homsi G, Busey A, Allen J, Vallone D. Initiation with menthol cigarettes and youth smoking uptake. Addiction 2013;108(1):171–8.22862154
Odani S, Armour BS, Graffunder CM, Garrett BE, Agaku IT. Prevalence and disparities in tobacco product use among American Indians/Alaska Natives—United States, 2010–2015. Morbidity and Mortality Weekly Report 2017;66(50):1374–8.29267265
Okoro CA, Hollis ND, Cyrus AC, Griffin-Blake S. Prevalence of disability and health care access by disability status and type among adults–United States, 2016. Morbidity and Mortality Weekly Report 2018;67(32):882–7.30114005
Oredein T, Foulds J. Causes of the decline in cigarette smoking among African American youths from the 1970s to the 1990s. American Journal of Public Health 2011;101(10):e4–e14.
Pampel FC. Racial convergence in cigarette use from adolescence to the mid-thirties. Journal of Health and Social Behavior 2008;49(4):484–98.19181051
Pampel FC. The persistence of educational disparities in smoking. Social Problems 2009;56(3):526–42.
Parker MA, Villanti AC. Relationship between comorbid drug use disorders, affective disorders, and current smoking. Substance Use & Misuse 2021;56(1):93–100.33143491
Parker MA, Weinberger AH, Eggers EM, Parker ES, Villanti AC. Trends in rural and urban cigarette smoking quit ratios in the U.S. from 2010 to 2020. JAMA Network Open 2022;5(8):e2225326.35921112
Patterson JG, Jabson JM, Bowen DJ. Measuring sexual and gender minority populations in health surveillance. LGBT Health 2017;4(2):82–105.28287877
Pesko MF, Robarts AMT. Adolescent tobacco use in urban versus rural areas of the United States: the influence of tobacco control policy environments. Journal of Adolescent Health 2017;61(1):70–6.
Pirkle JL, Bernert JT, Caudill SP, Sosnoff CS, Pechacek TF. Trends in the exposure of nonsmokers in the U.S. population to secondhand smoke: 1988–2002. Environmental Health Perspectives 2006;114(6):853–8.16759984
Prochaska JJ. Failure to treat tobacco use in mental health and addiction treatment settings: a form of harm reduction? Drug and Alcohol Dependence 2010;110(3):177–82.20378281
Proescholdbell SK, Foley KL, Johnson J, Malek SH. Indoor air quality in prisons before and after implementation of a smoking ban law. Tobacco Control 2008;17(2):123–7.18285386
Ramo DE, Liu H, Prochaska JJ. Tobacco and marijuana use among adolescents and young adults: a systematic review of their co-use. Clinical Psychology Review 2012;32(2):105–21.22245559
Redwood D, Lanier AP, Renner C, Smith J, Tom-Orme L, Slattery ML. Differences in cigarette and smokeless tobacco use among American Indian and Alaska Native people living in Alaska and the Southwest United States. Nicotine & Tobacco Research 2010;12(7):791–6.20525781
Roberts ME, Colby SM, Lu B, Ferketich AK. Understanding tobacco use onset among African Americans. Nicotine & Tobacco Research 2016a;18(Suppl 1)S49–S56.26980864
Roberts ME, Doogan NJ, Kurti AN, Redner R, Gaalema DE, Stanton CA, White TJ, Higgins ST. Rural tobacco use across the United States: how rural and urban areas differ, broken down by census regions and divisions. Health & Place 2016b;39:153–9.27107746
Roberts ME, Doogan NJ, Stanton CA, Quisenberry AJ, Villanti AC, Gaalema DE, Keith DR, Kurti AN, Lopez AA, Redner R, . Rural versus urban use of traditional and emerging tobacco products in the United States, 2013–2014. American Journal of Public Health 2017;107(10):1554–9.28817323
Rock VJ, Davis SP, Thorne SL, Asman KJ, Caraballo RS. Menthol cigarette use among racial and ethnic groups in the United States, 2004–2008. Nicotine & Tobacco Research 2010;12(Suppl 2):S117–S124.21177368
Rose SW, Amato MS, Anesetti-Rothermel A, Carnegie B, Safi Z, Benson AF, Czaplicki L, Simpson R, Zhou Y, Akbar M, . Characteristics and reach equity of policies restricting flavored tobacco product sales in the United States. Health Promotion Practice 2020;21(1 Suppl):44S–53S.31908207
Ross JC, Suerken CK, King JL, Wiseman KD, Noar SM, Wagoner KG, Sutfin EL. Adolescents’ first tobacco product: results from a nationally representative survey. Tobacco Regulatory Science 2018;4(3):38–46.
Satcher D. The history of the Public Health Service and the Surgeon General’s priorities. Food and Drug Law Journal 1999;54(1):13–9.11757554
Schauer GL, Berg CJ, Kegler MC, Donovan DM, Windle M. Assessing the overlap between tobacco and marijuana: trends in patterns of co-use of tobacco and marijuana in adults from 2003–2012. Addictive Behaviors 2015;49:26–32.26036666
Schauer GL, Rosenberry ZR, Peters EN. Marijuana and tobacco co-administration in blunts, spliffs, and mulled cigarettes: a systematic literature review. Addictive Behaviors 2017;64:200–11.27654966
Schiller JS, Lucas JW, Peregoy J, A. Summary Health Statistics for U.S. Adults: National Health Interview Survey, 2011. Vital Health Statistics Series 10, Number 256. Hyattsville (MD): National Center for Health Statistics, 2011. DHHS Publication No. (PHS) 2013–1584.
Schulz JA, Parker MA, Villanti AC. Trends in cigarette smoking prevalence and cessation in people with disabilities, 2015–2020. Poster presented at the 2022 Society for Research on Nicotine and Tobacco Annual Meeting; March 15–18, 2022a; Baltimore (MD).
Schulz JA, West JC, Hall JP, Villanti AC. Disparities in tobacco use by disability and type: findings from the 2019 National Health Interview Survey. American Journal of Preventive Medicine. 2022b;63(4):552–63.35753866
Seaman EL, Corcy N, Chang JT, Chomenko D, Hartman AM, Kittner DL, Reyes-Guzman CM. Menthol cigarette smoking trends among United States adults, 2003–2019. Cancer Epidemiology, Biomarkers & Prevention 2022;31(10):1959–65.
Shiffman S, Dunbar MS, Li X, Scholl SM, Tindle HA, Anderson SJ, Ferguson SG. Smoking patterns and stimulus control in intermittent and daily smokers. PLoS One 2014;9(3):e89911.24599056
Siahpush M, Singh GK, Jones PR, Timsina LR. Racial/ethnic and socioeconomic variations in duration of smoking: results from 2003, 2006 and 2007 Tobacco Use Supplement to the Current Population Survey. Journal of Public Health (Oxford) 2010;32(2):210–8.
Silveira ML, Green VR, Iannaccone R, Kimmel HL, Conway KP. Patterns and correlates of polysubstance use among U.S. youth aged 15–17 years: wave 1 of the Population Assessment of Tobacco and Health (PATH) Study. Addiction 2019;114(5):907–16.30614093
Simonavicius E, McNeill A, Shahab L, Brose LS. Heat-notburn tobacco products: a systematic literature review. Tobacco Control 2019;28(5):582–94.30181382
Smith PH, Assefa B, Kainth S, Salas-Ramirez KY, McKee SA, Giovino GA. Use of mentholated cigarettes and likelihood of smoking cessation in the United States: a meta-analysis. Nicotine & Tobacco Research 2020a;22(3):307–16.31204787
Smith PH, Chhipa M, Bystrik J, Roy J, Goodwin RD, McKee SA. Cigarette smoking among those with mental disorders in the U.S. population: 2012–2013 update. Tobacco Control 2020b;29(1):29–35.30377242
Smith PH, Mazure CM, McKee SA. Smoking and mental illness in the U.S. population. Tobacco Control 2014a;23(e2):e147–e153.24727731
Smith SS, Fiore MC, Baker TB. Smoking cessation in smokers who smoke menthol and non-menthol cigarettes. Addiction 2014b;109(12):2107–17.24938369
Stahre M, Okuyemi KS, Joseph AM, Fu SS. Racial/ethnic differences in menthol cigarette smoking, population quit ratios and utilization of evidence-based tobacco cessation treatments. Addiction 2010;105(Suppl 1):75–83.21059138
Steinberg ML, Williams JM, Li Y. Poor mental health and reduced decline in smoking prevalence. American Journal of Preventive Medicine 2015;49(3):362–9.26071864
Streck JM, Weinberger AH, Pacek LR, Gbedemah M, Goodwin RD. Cigarette smoking quit rates among persons with serious psychological distress in the United States from 2008 to 2016: are mental health disparities in cigarette use increasing? Nicotine & Tobacco Research 2020;22(1):130–4.30351429
Substance Abuse and Mental Health Services Administration. 2019 National Survey on Drug Use and Health (NSDUH): Methodological Summary and Definitions—NSDUH Methodological Report, September 2020; <https://www.samhsa.gov/data/report/2019-methodological-summary-and-definitions>; accessed: February 7, 2024.
Substance Abuse and Mental Health Services Administration. Key Substance Use and Mental Health Indicators in the United States: Results from the 2021 National Survey on Drug Use and Health (HHS Publication No. PEP22-07-01-005, NSDUH Series H-57), 2022; <https://www.samhsa.gov/data/report/2021-nsduh-annual-national-report>; accessed: February 7, 2024.
Szatkowski L, McNeill A. Diverging trends in smoking behaviors according to mental health status. Nicotine & Tobacco Research 2015;17(3):356–60.25180078
Talbot JA, Williamson ME, Pearson K, Lenardson J, Ziller E, Jimenez F, Paluso N, Munk L, Janis J, Clayton PF. Advancing Tobacco Prevention and Control in Rural America. Washington (DC): National Network of Public Health Institutes, 2019.
Thompson AB, Mowery PD, Tebes JK, McKee SA. Time trends in smoking onset by sex and race/ethnicity among adolescents and young adults: findings From the 2006–2013 National Survey on Drug Use and Health. Nicotine & Tobacco Research 2018;20(3):312–20.28339616
Tice P, Lipari RN, Van Horn SL. Substance use among 12th grade aged youths, by dropout status. Rockville (MD): Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, 2017; <https://www.samhsa.gov/data/sites/default/files/report_3196/ShortReport-3196.html>; accessed: February 4, 2020.
Tobacco Products Scientific Advisory Committee. Menthol Cigarettes and Public Health: Review of the Scientific Evidence and Recommendations. Washington (DC): U.S. Food and Drug Administration, 2011.
Tong E, Saito N, Tancredi DJ, Borges G, Kravitz RL, Hinton L, Aguilar-Gaxiola S, Medina-Mora ME, Breslau J. A transnational study of migration and smoking behavior in the Mexican-origin population. American Journal of Public Health 2012;102(11):2116–22.22994190
Tong EK, Gildengorin G, Nguyen T, Tsoh J, Modayil M, Wong C, McPhee SJ. Smoking prevalence and factors associated with smoking status among Vietnamese in California. Nicotine & Tobacco Research 2010;12(6): 613–21.20488931
Tonkin AM, Beauchamp A, Stevenson C. The importance of extinguishing secondhand smoke. Circulation 2009;120(14):1339–41.19770389
Trapl ES, Koopman Gonzalez SJ, Cofie L, Yoder LD, Frank J, Sterling KL. Cigar product modification among high school youth. Nicotine & Tobacco Research 2018;20(3):370–6.28003508
Trinidad DR, Gilpin EA, Lee L, Pierce JP. Do the majority of Asian-American and African-American smokers start as adults? American Journal of Preventive Medicine 2004;26(2):156–8.14751329
Trinidad DR, Pérez-Stable EJ, White MM, Emery SL, Messer K. A nationwide analysis of U.S. racial/ethnic disparities in smoking behaviors, smoking cessation, and cessation-related factors. American Journal of Public Health 2011;101(4):699–706.21330593
Tsai J, Homa DM, Gentzke AS, Mahoney M, Sharapova SR, Sosnoff CS, Caron KT, Wang L, Melstrom PC, Trivers KF. Exposure to secondhand smoke among nonsmokers—United States, 1988–2014. Morbidity and Mortality Weekly Report 2018;67(48):1342–6.30521502
Tsai J, Homa DM, Neff LJ, Sosnoff CS, Wang L, Blount BC, Melstrom PC, King BA. Trends in secondhand smoke exposure, 2011–2018: impact and implications of expanding serum cotinine range. American Journal of Preventive Medicine 2021;61(3):e109–e117.34419235
U.S. Bureau of Labor Statistics. Standard occupational classification, n.d.; <https://www.bls.gov/soc/2018/home.htm>; accessed: October 6, 2021.
U.S. Census Bureau. Improvements to the 2020 Census race and Hispanic origin question designs, data processing, and coding procedures, August 3, 2021; <https://www.census.gov/newsroom/blogs/random-samplings/2021/08/improvements-to-2020-census-race-hispanic-origin-question-designs.html>; accessed: November 1, 2022.
U.S. Census Bureau. Census regions and divisions of the United States, n.d.a; <https://www2.census.gov/geo/pdfs/maps-data/maps/reference/us_regdiv.pdf>; accessed: May 14, 2019.
U.S. Census Bureau. Poverty, n.d.b; <https://www.census.gov/topics/income-poverty/poverty.html>; accessed: March 1, 2020.
U.S. Census Bureau. Selected population profile in the United States—2019: ACS 1-year estimates selected population profiles, n.d.c; <https://data.census.gov/table/ACSSPP1Y2019.S0201?q=foreign%20born>; accessed: November 16, 2023.
U.S. Department of Health and Human Services. Tobacco Use Among U.S. Racial/Ethnic Minority Groups—African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1998.
U.S. Department of Health and Human Services. The Health Consequences of Smoking: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2004.
U.S. Department of Health and Human Services. The Health Consequences of Involuntary Exposure to Tobacco Smoke: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, Coordinating Center for Health Promotion, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2006.
U.S. Department of Health and Human Services. The Health Consequences of Smoking—50 Years of Progress: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2014.
U.S. Department of Health and Human Services. Sexual Orientation and Gender Identity (SOGI) Data Action Plan, n.d.; <https://www.hhs.gov/sites/default/files/hhs-sogi-data-action-plan.pdf>; accessed: February 7, 2024.
U.S. Department of Housing and Urban Development. Resident characteristics report (RCR), n.d.; <http://portal.hud.gov/hudportal/HUD?src=/program_offices/public_indian_housing/systems/pic/50058/rcr>; accessed: May 30, 2019.
U.S. Food and Drug Administration. Preliminary Scientific Evaluation of the Possible Public Health Effects of Menthol Versus Nonmenthol Cigarettes, 2013a; <https://www.fda.gov/media/86497/download>; accessed: February 19, 2019.
U.S. Food and Drug Administration. Reference Addendum: Preliminary Scientific Evaluation of the Possible Public Health Effects of Menthol Versus Nonmenthol Cigarettes. Silver Spring (MD): Center for Tobacco Products, Food and Drug Administration, 2013b.
U.S. Food and Drug Administration. FDA permits sale of IQOS Tobacco Heating System through premarket tobacco product application pathway [FDA news release], April 30, 2019; <https://www.fda.gov/news-events/press-announcements/fda-permits-sale-iqos-tobacco-heating-system-through-premarket-tobacco-product-application-pathway>; accessed: November 1, 2022.
United States International Trade Commission. In the Matter of Certain Tobacco Heating Articles and Components Thereof: Commission Opinion Denying Respondents’ Motion to Stay Limited Exclusion Order and Cease and Desist Orders Pending Appeal (Investigation No. 337-TA-1199), January 20, 2022; <https://www.fr.com/wp-content/uploads/2022/02/1199-Order-Denying-Stay.pdf>; accessed: November 7, 2022.
Vander Weg MW, Cunningham CL, Howren MB, Cai X. Tobacco use and exposure in rural areas: findings from the Behavioral Risk Factor Surveillance System. Addictive Behaviors 2011;36(3):231–6.21146318
Villanti AC, Collins LK, Niaura RS, Gagosian SY, Abrams DB. Menthol cigarettes and the public health standard: a systematic review. BMC Public Health 2017;17(1):983.29284458
Villanti AC, Johnson AL, Glasser AM, Rose SW, Ambrose BK, Conway KP, Cummings KM, Stanton CA, Edwards KC, Delnevo CD, . Association of flavored tobacco use with tobacco initiation and subsequent use among U.S. youth and adults, 2013–2015. JAMA Network Open 2019;2(10):e1913804.31642927
Villanti AC, Johnson AL, Halenar MJ, Sharma E, Cummings KM, Stanton CA, Delnevo CD, Wackowski OA, Bansal-Travers M, Pearson JL, . Menthol and mint cigarettes and cigars: initiation and progression in youth, young adults and adults in Waves 1–4 of the PATH Study, 2013–2017. Nicotine & Tobacco Research 2021;23(8):1318–26.33159209
Villanti AC, Mowery PD, Delnevo CD, Niaura RS, Abrams DB, Giovino GA. Changes in the prevalence and correlates of menthol cigarette use in the U.S.A., 2004–2014. Tobacco Control 2016;25(Suppl 2):ii14–ii20.27729565
Vupputuri S, Hajat C, Al-Houqani M, Osman O, Sreedharan J, Ali R, Crookes AE, Zhou S, Sherman SE, Weitzman M, . Midwakh/dokha tobacco use in the Middle East: much to learn. Tobacco Control 2016;25(2):236–41.25342581
Walton K, Gentzke AS, Murphy-Hoefer R, Kenemer B, Neff LJ. Exposure to secondhand smoke in homes and vehicles among U.S. youths, United States, 2011–2019. Preventing Chronic Disease 2020;17:E103.32915130
Wang TW, Gentzke AS, Creamer MR, Cullen KA, Holder-Hayes E, Sawdey MD, Anic GM, Portnoy DB, Hu S, Homa DM, . Tobacco product use and associated factors among middle and high school students—United States, 2019. Morbidity and Mortality Weekly Report Surveillance Summaries 2019;68(12):1–22.
Wang Y, Sung HY, Yao T, Lightwood J, Max W. Infrequent and frequent non-daily smokers and daily smokers: their characteristics and other tobacco use patterns. Nicotine & Tobacco Research 2018;20(6):741–8.28186549
Weglicki LS, Templin TN, Rice VH, Jamil H, Hammad A. Comparison of cigarette and water-pipe smoking by Arab and non-Arab-American youth. American Journal of Preventive Medicine 2008;35(4):334–9.18675529
Weinberger AH, Streck JM, Pacek LR, Goodwin RD. Non-Daily cigarette smoking is increasing among people with common mental health and substance use problems in the United States: data from representative samples of U.S. adults, 2005–2014. Journal of Clinical Psychiatry 2018;79(5).
Weinberger AH, Zhu J, Barrington-Trimis JL, Wyka K, Goodwin RD. Cigarette use, e-cigarette use, and dual product use are higher among adults with serious psychological distress in the United States: 2014–2017. Nicotine & Tobacco Research 2020;22(10):1875–82.32285121
Wheldon CW, Wiseman KP. Tobacco use among transgender and gender non-conforming adults in the United States. Tobacco Use Insights 2019;12:1179173X19849419.
Wiggins AT, Huntington-Moskos L, Rayens EA, Rayens MK, Noland M, Butler K, Hahn EJ. Tobacco use among rural and urban U.S. middle and high school students: National Youth Tobacco Survey, 2011–2016. Journal of Rural Health 2020;36(1):48–54.
Wilson KM, Torok MR, McMillen RC, Klein JD, Levy DE, Winickoff JP. Tobacco-smoke incursions and satisfaction among residents with children in multiunit housing, United States, 2013. Public Health Reports 2017;132(6):637–45.28977766
Yao T, Sung HY, Wang Y, Lightwood J, Max W. Sociodemographic differences among U.S. children and adults exposed to secondhand smoke at home: National Health Interview Surveys 2000 and 2010. Public Health Reports 2016;131(2):357–66.26957671
Yerger V, Pearson C, Malone RE. When is a cigar not a cigar? African American youths’ understanding of “cigar” use. American Journal of Public Health 2001;91(2):316–7.11211649
Zhu S-H, Wong S, Tang H, Shi CW, Chen MS. High quit ratio among Asian immigrants in California: implications for population tobacco cessation. Nicotine & Tobacco Research 2007;9(Suppl 3):S505–S514.17978979
Ziller EC, Lenardson JD, Paluso NC, Talbot JA, Daley A. Rural-Urban differences in the decline of adolescent cigarette smoking. American Journal of Public Health 2019;109(5):771–3.30897002

## Chapter 2 Appendices

### Appendix 2.1 Sources of Data

Primary data analyzed and summarized in this chapter come from cross-sectional data obtained through seven national surveillance systems: the Youth Risk Behavior Surveillance System (YRBSS), the National Youth Tobacco Survey (NYTS), the National Survey on Drug Use and Health (NSDUH), the National Health Interview Survey (NHIS), the Tobacco Use Supplement to the Current Population Survey (TUS-CPS), the Behavioral Risk Factor Surveillance System (BRFSS), and the National Health and Nutrition Examination Survey (NHANES) (Table 2.1). Analyses were conducted on weighted data accounting for the complex sampling design. These systems are described in the following sections.

#### Youth Risk Behavior Surveillance System

Developed in 1990 by the Centers for Disease Control and Prevention (CDC), the Youth Risk Behavior Surveillance System (YRBSS) monitors priority health risk behaviors. In addition to the surveys that are conducted by state, local, territorial, and tribal health and education agencies, there is a national YRBS (Youth Risk Behavior Survey) conducted by CDC. The current report includes data from the national YRBS only, which has a sampling frame of all public and private school students in Grades 9–12 in the 50 states and the District of Columbia. A three-stage cluster sample design is used to sample (1) large-sized counties or groups of smaller adjacent counties, (2) public and private schools with a probability proportional to the schools’ enrollment, and (3) one or two randomly selected classes in each grade. Examples of classes include homerooms; classes of a required discipline, such as English or social studies; and all classes meeting during a required period, such as second period. All students in a sampled class are eligible to participate. Oversampling is used to achieve sufficiently large subsamples of Black and Hispanic students to enable separate analyses of these populations. Schools that decline to participate in the original sample are not replaced.

Students complete self-administered, paper-and-pencil questionnaires and record their answers directly in the questionnaire booklet or on a separate computer-scannable answer sheet (CDC 2013). Local procedures are followed to obtain the permission of parents. Trained personnel administer the questionnaires to students in their classrooms for the national survey and for most state and local surveys. The participation of students is both voluntary and anonymous (CDC 2013). In 2019, 13,677 students in Grades 9–12 participated in the national YRBS. The overall response rate was 60.3%, which is the product of the school-level response rate (49.9%) and the student-level response rate (80.3%) (Table 2.1).

#### National Youth Tobacco Survey

The National Youth Tobacco Survey (NYTS) is a nationally representative, school-based, self-administered survey of U.S. middle school students (Grades 6–8) and high school students (Grades 9–12). The NYTS was first administered in 1999 and has been administered annually since 2011. It is currently funded by the CDC and the U.S. Food and Drug Administration (FDA). The NYTS transitioned to an electronic survey administration in 2019. It provides national data on long-term, intermediate, and short-term indicators key to the design, implementation, and evaluation of comprehensive tobacco prevention and control programs. The NYTS also serves as a baseline for comparing progress toward meeting selected Healthy People 2030 goals for reducing tobacco use among youth (CDC n.d.c). Items measured as part of the NYTS survey include ever and past-30-day use of a variety of tobacco products and correlates of tobacco use such as demographics, minors’ access to tobacco, and exposure to secondhand tobacco smoke. In 2020, 14,531 students in Grades 6–12 participated in the NYTS. The overall response rate was 49.9%, which is the product of the school-level response rate (49.9%) and the student-level response rate (87.4%) (Table 2.1). However, data collection for the 2020 NYTS ended early because of school-related closures and other emergency protocols related to the COVID-19 pandemic (Office on Smoking and Health 2020).

#### National Survey on Drug Use and Health

The National Survey on Drug Use and Health (NSDUH) is an annual survey of the civilian, noninstitutionalized population of the United States 12 years of age and older. Before 2002, this survey, which has been conducted by the federal government since 1971, was called the National Household Survey on Drug Abuse. The NSDUH is the primary source of statistical information on the use of illegal drugs by the U.S. population; face-to-face interviews are used to collect confidential data from a representative sample of the population at their place of residence. The survey is sponsored by the Substance Abuse and Mental Health Services Administration (SAMHSA), an agency within the U.S. Department of Health and Human Services (USDHHS), and is planned and managed by SAMHSA’s Center for Behavioral Health Statistics and Quality (SAMHSA 2009b).

Since 1999, SAMHSA has implemented major improvements in the methods used in this survey (SAMHSA 2009a). Data are collected using computer-assisted interviewing, and respondents are given a US$30 incentive payment for participation. The samples in the 2005–2013 NSDUHs were allocated equally between three age groups: 12–17 years of age, 18–25 years of age, and 26 years of age and older. Starting in 2014 and continuing through 2019, the allocation of the NSDUH sample was 25% for adolescents (12–17 years of age), 25% for young adults (18–25 years of age), and 50% for adults (26 years of age and older). The sample of adults was further divided into three subgroups: 26–34 years of age (15%), 35–49 years of age (20%), and 50 years of age and older (15%) (SAMHSA 2020). The NSDUH sampling frame includes civilian residents of non-institutional group quarters (e.g., shelters, rooming houses, dormitories, and group homes), residents of each state and the District of Columbia, and civilians living on military bases. People excluded from the universe were those with no fixed household address (e.g., homeless transients not in shelters), active-duty military personnel, and residents of institutional group quarters (e.g., jails, prisons, or hospitals). The NSDUH employed a state-based design with an independent, multistage area probability sample within each state and Washington, D.C. The eight states with the largest populations (California, Florida, Illinois, Michigan, New York, Ohio, Pennsylvania, and Texas), which together account for about one-half of the total U.S. population 12 years of age and older, were designated as large-sample states and had varying target samples between 2,400 and 4,560 respondents. For the remaining 42 states and Washington, D.C., the target sample ranged from 960 to 1,500 respondents per state (SAMHSA 2020). Combining data over multiple survey years allows for direct estimates for all states. In 2019, the NSDUH had a weighted screening response rate of 70.5% and a weighted interview response rate of 64.9% (Table 2.1). A total of 67,625 people were included in the main sample of the 2019 restricted-use dataset. NSDUH public use files with 56,136 people included from the 2019 sample are available for download and online analysis (http://www.samhsa.gov).

#### National Health Interview Survey

The National Health Interview Survey (NHIS), a multipurpose household survey conducted by the National Center for Health Statistics of CDC, is the principal source of information on the health of the civilian, noninstitutionalized population of the United States. The NHIS has been conducted continuously since 1957. Questions on smoking have been included in selected survey years since 1965, and detailed items allowing classification by race and ethnicity have been included since 1978. Detailed questions on tobacco use are included in a Cancer Control Supplement to the NHIS, which started in 1987 and was subsequently conducted in 1992, 2000, 2005, 2010, and 2015. In 2019, the content and structure of the NHIS were updated. The redesigned questionnaire includes four components: the annual core, rotating core, sponsored content, and emerging topics. Questions about cigarette and e-cigarette use are asked every year as part of the annual core. Questions about noncigarette tobacco product use also are asked annually as part of content sponsored by FDA. Remaining questions on smoking history and cessation are included in the rotating core; beginning in 2020, these questions are included every other year on the NHIS (CDC n.d.b).

The current sampling plan follows an area probability design that permits the representative sampling of households and noninstitutional group living quarters in all 50 states and the District of Columbia. From each household, one sample adult and one sample child (younger than 18 years of age) are randomly selected to complete a more detailed interview about their health. Interviews are conducted in person but follow-up may be conducted by telephone when necessary. Questions on tobacco use are only asked among sample adults. In 2021, 29,482 adults (18 years of age and older) participated in the NHIS (response rate = 50.9%) (National Center for Health Statistics 2022). More detailed information is available at https://www.cdc.gov/nchs/nhis/index.htm.

#### Tobacco Use Supplement to the Current Population Survey

The Tobacco Use Supplement to the Current Population Survey (TUS-CPS) is a National Cancer Institute (NCI)-sponsored survey of tobacco use that has been administered as part of the U.S. Census Bureau’s Current Population Survey about every 3 to 4 years since 1992–1993 (since 2000, surveys were conducted for 2001–2002, 2003, 2006–2007, 2010–2011, 2014–2015, and 2018–2019). In each cycle, the TUS-CPS collects nationally representative data from about 240,000 adults (data collected between 1992 and 2006 also included youth 15–17 years of age). About two-thirds of respondents complete the questionnaire by telephone, and responses for the remaining one-third are obtained through in-person interviews. In the 2018–2019 TUS-CPS, 137,471 respondents were interviewed; the average response rate was 57.6% for the 2018–2019 cycle (Table 2.1). More detailed information about the TUS-CPS is available from NCI (n.d.).

#### Behavioral Risk Factor Surveillance System

In 1984, CDC initiated the state-based Behavioral Risk Factor Surveillance System (BRFSS). This cross-sectional, random-digit-dial telephone survey is conducted monthly by state health departments over landline and cellular telephones (included since 2011) using a standardized questionnaire and technical and methodologic assistance provided by CDC. The BRFSS is used to collect data among U.S. adults 18 years of age and older regarding their risk behaviors and preventive health practices that can affect their health status. Data from respondents are forwarded to CDC to be aggregated for each state, returned with standard tabulations, and published at year’s end by each state. In 2011, the BRFSS adopted new methods, including the addition of households with cellular telephones to its sample, and used new methods of weighting to adjust survey data for differences between the demographic characteristics of respondents and the survey population (CDC 2012). As a result of these methodologic changes, data after 2011 cannot be compared with the years before 2011. In 2020, more than 400,000 interviews were conducted with respondents from all 50 states, the District of Columbia, and participating U.S. territories and other geographic areas. The median response rate was 47.9%. For this Surgeon General’s report, data have been weighted to reflect the age, race and ethnicity, and sex distribution in each participating state. CDC (n.d.a) offers detailed information about the BRFSS.

#### National Health and Nutrition Examination Survey

Beginning in 1988, researchers have used serum cotinine measurements to assess exposure to secondhand tobacco smoke in the United States within the National Health and Nutrition Examination Survey (NHANES). The NHANES is conducted by CDC’s National Center for Health Statistics (NCHS) and is designed to examine a nationally representative sample of the U.S. civilian (noninstitutionalized) population based on a complex, stratified, multistage probability cluster sampling design (see http://www.cdc.gov/nchs/nhanes.htm). The protocols include a home interview followed by a health examination in a mobile examination center, where blood samples are drawn for serum cotinine analysis. NHANES III, conducted from 1988 to 1994, was the first national survey of exposure to secondhand tobacco smoke in the entire U.S. population 4–74 years of age. There were two phases: Phase 1 from 1988 to 1991, and Phase 2 from 1991 to 1994. There were no further studies between 1995 and 1998. In 1999, NCHS resumed NHANES on a continuous basis and released public use data for a nationally representative sample every 2 years. This continuous NHANES (1999 to present) also began to draw blood samples for serum cotinine analyses from participants 3 years of age and older.

All analyses were performed on mobile examination center weighted data to provide nationally representative estimates. Researchers have reported serum cotinine levels in people who did not smoke from the NHANES for Phase 1 and Phase 2 of NHANES III, NHANES 1999–2000, NHANES 2001–2002, and 1988–2014 (Pirkle et al. 1996, 2006; Homa et al. 2015; Tsai et al. 2018). Researchers have reported additional data on serum cotinine levels in people who did not smoke from NHANES 1999–2010 in the Fourth National Report on Human Exposure to Environmental Chemicals (CDC 2015). Trend data are reported for participants 4 years of age and older during NHANES III 1988–1994 and 3 years of age and older during NHANES 1999–2014 (Pirkle et al. 2006; Homa et al. 2015; Tsai et al. 2018). Factors that affect nicotine metabolism, such as age, race, and the level of exposure to secondhand tobacco smoke, also influence cotinine levels (Caraballo et al. 1998; Mannino et al. 2001). Because cotinine levels reflect exposures that occurred within 2 to 3 days, they represent patterns of usual exposure (Jarvis et al. 1987; Benowitz 1996; Jaakkola and Jaakkola 1997).

Studies have documented NHANES-obtained serum cotinine levels in both children and adults who did not smoke (Pirkle et al. 1996, 2006; CDC 2001, 2003, 2005; Homa et al. 2015; Tsai et al. 2018). To maintain comparability among survey intervals, non-smoking adults were defined in these studies as people whose serum cotinine concentrations were 10 nanograms per milliliter (ng/mL) or less and who did not report currently smoking during a household interview or using any nicotine-containing product within the preceding 5 days at a mobile examination center interview. In NHANES III, the laboratory limit of detection was 0.050 ng/mL. Laboratory methods have continued to improve, however, and the detection limit was recently lowered to 0.015 ng/mL (CDC 2005; Pirkle et al. 2006). Additionally, researchers have categorized serum cotinine concentrations by age, race, and ethnicity. The racial and ethnic categories used are non-Hispanic White, non-Hispanic Black, Mexican American, and “Other,” and they are self-reported. The category of “Other” was included in these reports in mean and percentile estimates for the total population but because of small samples, people of “Other” races were not included in the estimates for geometric means (CDC 2005; Pirkle et al. 2006). In the 2017–2018 NHANES, 9,254 interviews were obtained, and 8,704 examinations were performed. The response rates were 51.9% for the interview sample and 48.8% for the examination sample (Table 2.1).

#### Methodologic Limitations

The literature on tobacco control acknowledges four main categories of methodologic limitations with regard to health disparities: (1) nongeneralizability, (2) noncomparability, (3) problems with sample size and aggregation, and (4) nonreporting (USDHHS 1998; NCI 2017). These and other methodologic limitations and challenges remain relevant today, as discussed here.

Within populations, including racial and ethnic groups, aggregate data can mask meaningful disparities in smoking behaviors. When national data cannot be disaggregated for such populations, trend data cannot be reported. This constraint often makes it difficult to report health disparities by sex, racial and ethnic group, and sexual orientation or to stratify health disparities indicators of SES, such as poverty level, educational attainment level, and occupation. In some cases, surveillance data are limited for groups known to be at high risk of tobacco use—such as the lesbian, gay, bisexual, transgender, queer, or intersex (LGBTQI+) community. National surveys are based on civilian household-based populations, so people experiencing homelessness, incarceration, or in a transient population are not included.

When group-specific data are reported, confidence intervals may be wide, which suggests that if the survey were conducted again with a different sample, estimates for the population parameter estimate may be different. Even when appropriate sampling methods are used, the results may have diminished reliability. In some cases, regional survey data will yield better estimates for certain aggregated and disaggregated groups and will reflect more stable estimates of tobacco use patterns.

Surveys often do not account for contextual factors, including socioecological factors, that may contribute to disparities in tobacco use and related disease outcomes. Intrapersonal-, interpersonal-, community/neighborhood-, and societal/policy-level factors continue to help explain the disparities that exist between racial and ethnic groups (Turner and Avison 2003) and are further explored in Chapter 4.

Studies may not collect data on all aspects of tobacco use that are important or unique to specific groups (e.g., menthol vs. nonmenthol cigarette use), or collect adequate data among specific populations (e.g., by sexual orientation and gender identity). As national surveys have begun to collect data on emerging tobacco products, including e-cigarettes, challenges have arisen because of the rapidly changing terms for new tobacco products, which in turn may lead to underestimation or misclassification of the use of tobacco products. Although national surveys are broadening their focus beyond conventional cigarettes, not all national surveys collect data on such products, distinguish by product, or monitor flavors used (or preferred) by different racial and ethnic or socioeconomic groups.

Finally, due to the COVID-19 pandemic, usual data collection procedures for some of the data sources reported in this chapter were interrupted beginning in March 2020. NHIS data collection was switched from in-person visits to telephone-only data collection from March to June 2020; thereafter, limited in-person visits resumed through December 2020. These changes resulted in potential loss of coverage and lower response rates; in response, some of the 2020 NHIS sample was replaced with a reinterview of respondents who completed the 2019 interview. These methodologic changes resulted in new procedures to conduct cross-sectional, pooled, and longitudinal data analyses (National Center for Health Statistics 2021). The NYTS, which previously collected data in person from students in schools, ended data collection procedures early (in March 2020) due to widespread school closures associated with the COVID-19 pandemic (Office on Smoking and Health 2020). A nonresponse analysis and subsequent adjustments to the weighting process were completed for 2020 data. The 2021 NYTS was administered online to allow eligible students to complete the survey at home or at school due to continued COVID-19 protocols in schools (Office on Smoking and Health 2021). As such, the data from the 2021 NYTS may not be comparable to results from previous surveys that were conducted primarily in person on school campuses. These methodologic changes to the NHIS and NYTS may have resulted in comparability issues across survey years. The BRFSS was previously conducted as a telephone-only survey (CDC 2021), so no changes in methodology were made as a result of the COVID-19 pandemic. However, the COVID-19 pandemic may also have had an impact on behavioral and lifestyle factors, including tobacco use, the direction of which is mixed (Nindenshuti and Caire-Juvera 2023).

### Appendix 2.2 Measures of Tobacco Use

#### Validity of Measures of Tobacco Product Use Among Youth

All data on tobacco product use among youth that are presented in this report are based on retrospective, self-reported responses to questionnaires. Because of the retrospective nature of data collection, and because tobacco use is viewed by many as a socially undesirable behavior, there is a risk of inaccurate responses. Because it was not feasible to verify the self-reported data included here, researchers should interpret these data with some degree of caution and an understanding of possible sources of inaccuracy. Many factors can affect the validity of self-reported data—factors that can be categorized as cognitive or situational. Cognitive processes that affect responses include comprehension of the question, retrieval of relevant information from memory, decision making about the adequacy of the information retrieved, and the generation of a response (Brener et al. 2003). Each of these processes can contribute to errors in responses and, subsequently, to problems with validity.

Situational factors that affect the validity of self-reported data refer to characteristics of the external environment in which the survey is being conducted. These include the setting (i.e., school or home based), the method (i.e., self-administered questionnaire or in-person interview), the social desirability of the behavior being reported, and the perception of privacy and/or confidentiality of responses (USDHHS 1994; Brener et al. 2003).

Many studies have found that youth report a higher number of sensitive behaviors when a survey is completed in a school setting rather than in their homes (Gfroerer et al. 1997; Hedges and Jarvis 1998; Kann et al. 2002). For example, Kann and colleagues (2002) compared the school-based national Youth Risk Behavior Survey (YRBS) with the household-based YRBS supplement to the National Health Interview Survey (NHIS). The study found that the school-based survey produced a significantly higher reporting of many sensitive behaviors, such as driving after drinking alcohol, binge drinking, and currently using cannabis and cocaine. In addition, four measures of various stages of the smoking uptake process were higher in the school-based survey but estimates of current cigarette use and frequent cigarette use, while elevated in the school-based survey, were not significantly different from estimates generated in the household-based survey. Few differences in nonsensitive behaviors were observed.

Two other studies (Gfroerer et al. 1997; Brener et al. 2003) indicated that although self-reported estimates of current use of alcohol and illicit drugs were higher in the school-based versus household-based surveys, estimates of current cigarette smoking were quite similar across settings. All three of these studies (i.e., Gfroerer et al. 1997; Kann et al. 2002; Brener et al. 2003) used self-administered rather than interviewer-administered interviews or questionnaires. Regardless, the provision of privacy that school surveys feature is important, especially if tobacco use, including e-cigarettes, becomes more socially unacceptable over time. Notably, household-based surveys are relatively more likely to include youth who drop out of school or are frequently absent from school, who are more likely to smoke.

Self-administered methods of data collection have generally produced higher reporting of sensitive behaviors, including tobacco use, than have interviewer-administered methods (Turner et al. 1992; Aquilino 1994; Brittingham et al. 1998). For example, Turner and colleagues (1992) found that the prevalence of current smoking among 12- to 17-year-olds based on reports in the self-administered version of the National Survey on Drug Use and Health (NSDUH) home-based survey was considerably higher (by 10–30%) than it was using the interviewer-administered version. The absence of personal interaction with an interviewer on self-administered surveys may reduce the reporting biases associated with perceived privacy and the social desirability of a behavior (Brener et al. 2003).

In conclusion, the factors described previously may affect the point estimates of smoking prevalence, but if these factors remain stable over the years, they should not affect the trends seen over time.

#### Validity of Measures of Tobacco Use Among Adults

All data on tobacco use among adults that were presented in this report were based on retrospective self-reported responses to questionnaires. Biochemical validation studies suggest that data on self-reported cigarette smoking are generally valid, except in certain situations, such as in conjunction with intense smoking cessation programs or with certain populations, such as pregnant women or adolescents in the presence of a parent (Velicer et al. 1992; Kendrick et al. 1995; USDHHS 2012). Misclassification may also be more common among people who intermittently smoke because they have lower biomarker levels of nicotine compared with people who smoke regularly or currently. However, Gutiérrez-Torres and colleagues (2021) reported a positive correlation between cotinine measures and number of days smoking and number of cigarettes smoked per month among non-daily smokers, indicating validity of self-reported smoking behaviors among people who intermittently smoke. Additionally, people who smoke may misreport the number of cigarettes smoked per day because of digit preference (preference for multiples of 10) (Klesges et al. 1995). Regardless, a meta-analysis of 26 validation studies (Patrick et al. 1994) and community data (Wong et al. 2012) found that self-reported smoking status is generally accurate compared with biomarker assessment. One study on self-reported smoking among youth also showed comparable validity across African American, Hispanic, and White adolescents (Wills and Cleary 1997). It should be noted here that much of the research literature on the validity of self-reported data is restricted to cigarette smoking—cigars, smokeless tobacco, and other tobacco or nicotine products are rarely addressed. As such, a discussion of the factors that may affect validity is warranted so that the data presented in the present report are interpreted with some caution and an understanding of possible sources of inaccuracy. Clearly, many factors can affect the validity of self-reported data, such as response biases and methodologic features of surveys.

Methodologic differences in survey administration—including but not limited to timing, the order of questions, sampling, data collection mode (e.g., computerassisted personal interviewing vs. computer-assisted telephone interviewing), participation rates, and operational definitions—can affect prevalence estimates of tobacco use (Ryan et al. 2012). The NHIS and NSDUH both use computer-assisted personal interviewing, which is done in the home. The NSDUH differs from the NHIS, however, with respect to the operational definition of cigarette smoking (Delnevo and Bauer 2009). The NHIS defines current smoking among adults as smoking at least 100 cigarettes during one’s lifetime and smoking every day or on some days. In contrast, the NSDUH defines current smoking for youth, young adults, and adults as smoking part or all of a cigarette during the past 30 days. The Substance Abuse and Mental Health Services Administration, which sponsors the NSDUH, does not use the 100 cigarettes-in-a-lifetime threshold when making estimates of the prevalence of cigarette smoking from NSDUH data. This likely contributes to the consistently higher estimates from the NSDUH noted in this report (see “Measures of Tobacco Use” section) (Ryan et al. 2012). Tables in this chapter continue the criteria described previously for youth and young adults. To help with comparisons with the NHIS, data in selected tables on all adults 18 years of age and older use the 100-cigarette threshold, as noted in the footnotes to the tables. Ryan and colleagues (2012) discuss these differences in the definitions of current smoking and how they could affect smoking estimates, particularly in some subpopulations. However, with the use of a modified NSDUH definition for current smoking that incorporated the 100-cigarettes-in-a-lifetime threshold, Ryan and colleagues (2012) observed that a notable number of sub-population estimates (e.g., for 26–34 years of age, Asian people, and Hispanic people) became comparable between the NSDUH and NHIS surveys for the year 2008.

Ryan and colleagues (2012) also noted other methodologic differences between the surveys beyond the current smoking definition that may contribute to the consistently higher estimates in the NSDUH, including survey mode, setting, context, and incentives. The NSDUH interview mode as of 2019 was strictly in person using computerassisted personal interviewing, which is thought to provide respondents with an enhanced sense of privacy. Although the NHIS is designed to be administered in person by the interviewer, some interviews are completed by telephone. Ryan and colleagues (2012) also noted that the context of the survey and question placement could be a factor contributing to higher self-reporting of smoking in the NSDUH. Within the NHIS context, smoking may be viewed as one of the most serious health behaviors about which respondents are asked. Within the NSDUH, in contrast, the survey content focuses almost entirely on substance use behaviors, both licit and illicit, and respondents may perceive smoking to be one of the more socially acceptable behaviors about which they are asked. Finally, since 2002, the NSDUH has been paying respondents a $30 incentive upon completion of the survey, while participation in the NHIS remains uncompensated. Although these factors may affect the point estimates of various tobacco use indicators, if the factors remain stable over the years, they should not affect the trends seen over time within a given survey. Still, direct comparisons of point estimates across surveys are not advised because of methodologic differences between them. Instead, readers should consider consistency in patterns across years for the same survey.

##### Measures of Tobacco Use

Measures of tobacco use differ slightly among surveys and by the target population. For each tobacco use measure, the definitions used in the various surveys are summarized here.

##### Current Cigarette Smoking: Youth

The YRBS defines current smoking among students as having smoked cigarettes on at least 1 day during the 30 days before the survey. In contrast, the NSDUH asks whether the respondent has smoked “part or all of a cigarette” during the past 30 days.

##### Current Cigarette Smoking: Adults

In the NHIS from 1965 to 1991, current smoking was defined as having smoked at least 100 cigarettes and answering “yes” to the question “Do you smoke cigarettes now?” Beginning in 1992, the NHIS assessed whether respondents smoked every day, some days, or not at all. Current smoking was defined as having smoked every day or some days. In contrast, the NSDUH defines current cigarette smoking as having smoked all or part of a cigarette during the past 30 days. The 100-cigarettes-in-a-lifetime threshold is not traditionally used by the NSDUH in reporting the prevalence of current cigarette smoking. This difference, in part, contributes to the consistently higher estimates from NSDUH data than from other surveys. In any event, the 100-cigarettes-in-a-lifetime threshold question was collected and used in the present report when giving estimates of prevalence for adults.

##### Intermittent and Daily Cigarette Smoking

In the NSDUH, daily smoking was defined as having smoked every day during the past 30 days, and intermittent smoking was defined as having smoked on 1–29 days. In the NHIS, daily smoking was defined as currently smoking every day, and intermittent smoking was defined as currently smoking on some days.

##### Attempts to Quit Smoking

An attempt to quit smoking was defined in this chapter as having quit smoking for more than 1 day during the previous year. Depending on the year of the survey, the NHIS asked about attempts to quit during the past year or in a lifetime. An example of a question is “During the past 12 months, have you stopped smoking for more than one day because you were trying to quit smoking?” For NHIS, attempts in the past year included people who (a) currently smoked cigarettes and reported having stopped smoking for more than 1 day during the past 12 months because they were trying to quit smoking and (b) quit smoking during the past year. The question and methods used to assess quit attempts in the BRFSS are similar to that of the NHIS: “During the past 12 months, have you stopped smoking for 1 day or longer because you were trying to quit smoking?” The TUS-CPS assessment of a past-year attempt to quit smoking cigarettes included (a) people who currently smoked cigarettes and who tried to quit smoking completely during the past 12 months, or who attempted to quit for at least 1 day during the past 12 months, or who made serious efforts to quit smoking even if it lasted less than 1 day during the past 12 months and (b) people who quit smoking during the past 12 months.

##### Polytobacco Use

Use of multiple tobacco products was defined as having used any combination of two or more tobacco products, depending on the products assessed in the survey. In surveys where e-cigarettes were assessed, they were defined as a tobacco product in reporting multiple tobacco product use.

##### Successful Cessation

The BRFSS asks, “How long has it been since you last smoked a cigarette, even one or two puffs?” Among people who currently smoked cigarettes and who quit smoking during the past year, those who responded that they had quit smoking cigarettes for more than 6 months during the past year were defined as having quit success. In the TUS-CPS, assessment of a sustained quit from cigarette smoking for 6 or more months included people who quit smoking for 6–12 months before the interview among people who currently smoked cigarettes for at least 2 years and among people who quit smoking during the past 12 months.

##### Current Use of Smokeless Tobacco

The NSDUH defines current use of smokeless tobacco as having used it during the 30 days before the survey. To determine current usage, the NSDUH asks whether the respondent has “used snuff, even once” and/or “used chewing tobacco, even once” during the past 30 days. An affirmative answer to either question categorizes that respondent as currently using such a product.

The YRBS defines current use of smokeless tobacco as having used chewing tobacco, snuff, dip, snus, or dissolvable tobacco products (e.g., Redman, Levi Garrett, Beech-Nut, Skoal, Skoal Bandits, Copenhagen, Camel Snus, Marlboro Snus, General Snus, Ariva, Stonewall, or Camel Orbs), not counting any electronic vapor products, on at least 1 day during the 30 days before the survey.

In the NHIS, respondents are first asked, “Smokeless tobacco products are placed in the mouth or nose and can include chewing tobacco, snuff, dip, snus (SNOOSE), or dissolvable tobacco. Have you ever used smokeless tobacco products even one time?” Those answering “yes” are then asked, “Do you now use smokeless tobacco products every day, some days, or not at all?” The NHIS defines current use of smokeless tobacco as having used chewing tobacco/snuff every day or some days.

##### Current Cigar Use

The NSDUH defines current cigar use as having smoked cigars during the 30 days before the survey. Cigars are defined as “big cigars, cigarillos, and even little cigars that look like cigarettes.” To determine current usage, the NSDUH asks whether the respondent has smoked “part or all of a cigar” during the past 30 days. An affirmative answer to either question categorizes that respondent as currently using such a product. The NHIS first asks, “Have you ever smoked a regular cigar, cigarillo, or little filtered cigar, even one time?” Those providing an affirmative response are asked “Do you now smoke regular cigars, cigarillos, or little filtered cigars every day, some days or not at all?” People who smoked cigars “every day” or “some days” are defined as currently smoking cigars. The YRBS defines current cigar use as having smoked cigars, cigarillos, or little cigars on at least 1 day during the 30 days before the survey.

##### Current Pipe Use

The NSDUH defines current pipe use as having used a pipe to smoke tobacco. People who report ever smoking tobacco in a pipe are asked, “During the past 30 days, that is, since [DATEFILL], have you smoked tobacco in a pipe, even once?” People who provide an affirmative response are defined as currently smoking pipes. The NHIS, however, defines pipe use as smoking tobacco in a regular pipe, water pipe, or hookah. People who report ever smoking a pipe filled with tobacco (either a regular pipe, water pipe, or hookah), even one time, are asked, “Do you now smoke pipe filled with tobacco—either regular pipes, water pipes, or hookahs—every day, some days, or not at all?” People who smoke pipes “every day” or “some days” are defined as currently smoking pipes.

The YRBS does not assess pipe use. The NYTS, however, assesses the use of pipes and hookahs, separately. For both products, current use is defined as having used either product on 1 or more days during the past 30 days.

### References

Aquilino WS. Interview mode effects in surveys of drug and alcohol use: a field experiment. Public Opinion Quarterly 1994;58(2):210–40.
Benowitz NL. Cotinine as a biomarker of environmental tobacco smoke exposure. Epidemiology Review 1996; 18(2):188–204.
Brener ND, Billy JO, Grady WR. Assessment of factors affecting the validity of self-reported health-risk behavior among adolescents: evidence from the scientific literature. Journal of Adolescent Health 2003;33(6):436–57.
Brittingham A, Tourangeau R, Kay W. Reports of smoking in a national survey: data from screening and detailed interviews, and from self- and interviewer-administered questions. Annals of Epidemiology 1998;8(6):393–401.9708875
Caraballo RS, Giovino GA, Pechacek TF, Mowery PD, Richter PA, Strauss WJ, Sharp DJ, Eriksen MP, Pirkle JL, Maurer KR. Racial and ethnic differences in serum cotinine levels of cigarette smokers: Third National Health and Nutrition Examination Survey, 1988–1991. JAMA: the Journal of the American Medical Association 1998;280(2):135–9.9669785
Centers for Disease and Control Prevention. Behavioral Risk Factor Surveillance System, Overview: BRFSS 2020, July 7, 2021; <https://www.cdc.gov/brfss/annual_data/2020/pdf/overview-2020-508.pdf>; accessed: May 31, 2023.
Centers for Disease Control and Prevention. National Report on Human Exposure to Environmental Chemicals. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, 2001.
Centers for Disease Control and Prevention. Second National Report on Human Exposure to Environmental Chemicals. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Environmental Health, 2003. NCEH Publication No 02-0716.
Centers for Disease Control and Prevention. Third National Report on Human Exposure to Environmental Chemicals. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Environmental Health, 2005. NCEH Publication No 05-0570.
Centers for Disease Control and Prevention. Methodologic changes in the Behavioral Risk Factor Surveillance System in 2011 and potential effects on prevalence estimates. Morbidity and Mortality Weekly Report 2012;61(22):410–3.22672976
Centers for Disease Control and Prevention. Methodology of the Youth Risk Behavior Surveillance System—2013. Morbidity and Mortality Weekly Report Recommendations and Reports 2013;62(RR-1):1–20.
Centers for Disease Control and Prevention. Fourth National Report on Human Exposure to Environmental Chemicals, February 2015; <https://www.cdc.gov/biomonitoring/pdf/FourthReport_UpdatedTables_Feb2015.pdf>; accessed: February 25, 2020.
Centers for Disease Control and Prevention. Behavioral Risk Factor Surveillance System: 2020 BRFSS survey data and documentation, n.d.a; <https://www.cdc.gov/brfss/annual_data/annual_2020.html>; accessed: April 5, 2023.
Centers for Disease Control and Prevention. National Health Interview Survey: Sample Adult Questionnaire, n.d.b; <https://www.cdc.gov/nchs/data/nhis/Sample-Adult-Questionnaire.pdf>; accessed: November 9, 2022.
Centers for Disease Control and Prevention. National Youth Tobacco Survey (NYTS), n.d.c; <https://www.cdc.gov/tobacco/data_statistics/surveys/nyts/index.htm>; accessed: March 1, 2022.
Delnevo CD, Bauer UE. Monitoring the tobacco use epidemic III: the host: data sources and methodological challenges. Preventive Medicine 2009;48(Suppl I):S16–S23.18851990
Gfroerer J, Wright D, Kopstein A. Prevalence of youth substance use: the impact of methodological differences between two national surveys. Drug and Alcohol Dependence 1997;47(1):19–30.9279494
Gutiérrez-Torres DS, Wang L, Blount BC, Xia B, Sosnoff CS, Shiels MS, Inoue-Choi M, Etemadi A, Freedman ND. Concentrations of cotinine and 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanol (NNAL) in U.S. non-daily cigarette smokers. Cancer Epidemiology, Biomarkers & Prevention 2021;30(6):1165–74.
Hedges B, Jarvis M. Cigarette smoking. In: Prescott-Clark P, Primatesta P, editors. Health Survey for England: The Health of Young People, ‘95–97. London (England): The Stationery Office, 1998:191–221.
Homa DM, Neff LJ, King BA, Caraballo RS, Bunnell RE, Babb SD, Garrett BE, Sosnoff CS, Wang L. Vital signs: disparities in nonsmokers’ exposure to secondhand smoke—United States, 1999–2012. Morbidity and Mortality Weekly Report 2015;64(4):103–8.25654612
Jaakkola MS, Jaakkola JJ. Assessment of exposure to environmental tobacco smoke. European Respiratory Journal 1997;10(10):2384–97.9387970
Jarvis MJ, Tunstall-Pedoe H, Feyerabend C, Vesey C, Saloojee Y. Comparison of tests used to distinguish smokers from nonsmokers. American Journal of Public Health 1987;77(11):1435–8.3661797
Kann L, Brener ND, Warren CW, Collins JL, Giovino GA. An assessment of the effect of data collection setting on the prevalence of health risk behaviors among adolescents. Journal of Adolescent Health 2002;31(4):327–35.
Kendrick JS, Zahniser SC, Miller N, Salas N, Stine J, Gargiullo PM, Floyd RL, Spierto FW, Sexton M, Metzger RW, . Integrating smoking cessation into routine public prenatal care: the Smoking Cessation in Pregnancy project. American Journal of Public Health 1995;85(2):217–22.7856781
Klesges RC, Debon M, Ray JW. Are self-reports of smoking rate biased? Evidence from the Second National Health and Nutrition Examination Survey. Journal of Clinical Epidemiology 1995;48(10):1225–33.7561984
Mannino DM, Caraballo R, Benowitz N, Repace J. Predictors of cotinine levels in U.S. children: data from the Third National Health and Nutrition Examination Survey. Chest 2001;120(3):718–24.11555498
National Cancer Institute. A Socioecological Approach to Addressing Tobacco-Related Health Disparities. Tobacco Control Monograph 22. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2017. NIH Publication No. 17-CA-8035A.
National Cancer Institute. Survey instruments, n.d.; <https://hints.cancer.gov/instrument.aspx>; accessed: August 15, 2017.
National Center for Health Statistics. Survey Description, National Health Interview Survey, 2020. Hyattsville (MD): National Center for Health Statistics, Centers for Disease Control and Prevention, September 2021.
National Center for Health Statistics. Survey Description, National Health Interview Survey, 2021. Hyattsville (MD): National Center for Health Statistics, Centers for Disease Control and Prevention, August 2022.
Nindenshuti PM, Caire-Juvera G. Changes in diet, physical activity, alcohol consumption, and tobacco use in adults during the COVID-19 pandemic: a systematic review. Inquiry 2023;60:469580231175780.37219073
Office on Smoking and Health. 2020 National Youth Tobacco Survey: Methodology Report. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2020.
Office on Smoking and Health. 2021 National Youth Tobacco Survey: Methodology Report. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, August 2021.
Patrick DL, Cheadle A, Thompson DC, Diehr P, Koepsell T, Kinne S. The validity of self-reported smoking: a review and meta-analysis. American Journal of Public Health 1994;84(7):1086–93.8017530
Pirkle JL, Bernert JT, Caudill SP, Sosnoff CS, Pechacek TF. Trends in the exposure of nonsmokers in the U.S. population to secondhand smoke: 1988–2002. Environmental Health Perspectives 2006;114(6):853–8.16759984
Pirkle JL, Flegal KM, Bernert JT, Brody DJ, Etzel RA, Maurer KR. Exposure of the U.S. population to environmental tobacco smoke: the Third National Health and Nutrition Examination Survey, 1988 to 1991. JAMA: the Journal of the American Medical Association 1996;275(16):1233–40.8601954
Ryan H, Trosclair A, Gfroerer J. Adult current smoking: differences in definitions and prevalence estimates—NHIS and NSDUH, 2008. Journal of Environmental and Public Health 2012;2012:918368.22649464
Substance Abuse and Mental Health Services Administration. Appendix A: description of the survey. In: Results from the 2008 National Survey on Drug Use and Health: National Findings. NSDUH Series H-36. Rockville (MD): U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Office of Applied Studies, 2009a:115–23. DHHS Publication No. SMA 09-4434.
Substance Abuse and Mental Health Services Administration. Results from the 2008 National Survey on Drug Use and Health: National Findings. NSDUH Series H-36. Rockville (MD): U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Office of Applied Studies, 2009b. DHHS Publication No. SMA 09-4434.
Substance Abuse and Mental Health Services Administration. 2019 National Survey on Drug Use and Health (NSDUH): Methodological Summary and Definitions—NSDUH Methodological Report, September 2020; <https://www.samhsa.gov/data/report/2019-methodological-summary-and-definitions>; accessed: February 7, 2004.
Tsai J, Homa DM, Gentzke AS, Mahoney M, Sharapova SR, Sosnoff CS, Caron KT, Wang L, Melstrom PC, Trivers KF. Exposure to secondhand smoke among nonsmokers—United States, 1988–2014. Morbidity and Mortality Weekly Report 2018;67(48):1342–6.30521502
Turner CF, Lessler JT, Devore J. Effects of mode of administration and wording on reporting of drug use. In: Turner CF, Lessler JT, Gfroerer J, editors. Survey Measurement of Drug Use: Methodological Studies. Rockville (MD): U.S. Department of Health and Human Services, Public Health Service, Substance Abuse and Mental Health Services Administration, 1992:177–219. DHHS Publication No. (ADM) 92-1929.
Turner RJ, Avison WR. Status variations in stress exposure: implications for the interpretation of research on race, socioeconomic status, and gender. Journal of Health and Social Behavior 2003;44(4):488–505.15038145
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Young People: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1994.
U.S. Department of Health and Human Services. Tobacco Use Among U.S. Racial/Ethnic Minority Groups—African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1998.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2012.
Velicer WF, Prochaska JO, Rossi JS, Snow MG. Assessing outcome in smoking cessation studies. Psychological Bulletin 1992;111(1):23–41.1539088
Wills TA, Cleary SD. The validity of self-reports of smoking: analyses by race/ethnicity in a school sample of urban adolescents. American Journal of Public Health 1997; 87(1):56–61.9065227
Wong SL, Shields M, Leatherdale S, Malaison E, Hammond D. Assessment of validity of self-reported smoking status. Health Reports 2012;23(1):47–53.22590805

1 Most federal surveillance systems that measure gender identity do not currently measure nonbinary as an identity (Federal Interagency Working Group on Improving Measurement of Sexual Orientation and Gender Identity in Federal Surveys 2016). Beginning in 2023, the NHIS will include a gender identity measure with the following responses: “male,” “female,” “transgender,” “nonbinary,” and “another gender.” Respondents may select more than one response (CDC 2023a).

2 In general, occupation classification codes from the U.S. Census Bureau can be used to classify occupational class. White-collar jobs can include occupational classification codes referring to management, business, and financial occupations; professional and related occupations; sales and related occupations; and office and administrative support occupations. The manual labor or blue-collar category can include occupation classification codes referring to construction and extraction occupations; installation, maintenance, and repair occupations; production occupations; and transportation and material moving occupations. The service category can include occupation classification codes referring to service occupations. Finally, the other category may include such occupation classification codes as farming, fishing, and forestry occupations and the armed forces.

3 Data presented in Figure 2.8 are based on findings of Ham and colleagues (2011). As such, the terminology used to describe each occupational category is consistent with that study.

4 Findings presented in Table 2.18 are a re-creation of Table 8.1 in NCI (2017). Thus, Table 2.18 retains the terminology used in NCI (2017).

5 Sometimes described in NSDUH reports as any mental illness or AMI (see SAMHSA 2022).