# Chapter 1 Introduction, Overview, Conclusions, and History of Tobacco-Related Health Disparities

## Introduction

Since 1964, the U.S. Surgeon General has released 34 reports on smoking and health. In 1998, the first Surgeon General’s report on tobacco-related health disparities, Tobacco Use Among U.S. Racial/Ethnic Minority Groups, examined four racial and ethnic groups (the aggregate groups of African American, American Indian and Alaska Native, Asian American and Pacific Islander, and Hispanic persons) (U.S. Department of Health and Human Services [USDHHS] 1998). Additional reports of the Surgeon General have examined health disparities to include additional factors beyond race and ethnicity, such as socioeconomic status (SES), age, educational attainment, and geography (USDHHS 2006, 2014, 2020). This Surgeon General’s report—the 35th on tobacco—summarizes current progress toward meeting the challenge of eliminating tobacco-related health disparities in the United States. Tobacco-related health disparities are defined for this report as “differences in

- the patterns, prevention, and treatment of tobacco use;
- the risk, incidence, morbidity, mortality, and burden of tobacco-related illness that exist among specific population groups in the United States; and
- related differences in capacity and infrastructure, access to resources, and [exposure to secondhand tobacco smoke]” (Fagan et al. 2004, p. 211).

This definition acknowledges that disparities can occur throughout the tobacco use continuum—from tobacco use initiation, to current tobacco use, to cessation-seeking behaviors and ultimately, cessation—and that disparities exist in numerous indicators, including the number of cigarettes smoked per day, access to and utilization of screening and treatment for tobacco product use and dependence, rates of cessation and relapse, health consequences of tobacco use, exposure to tobacco marketing, and exposure to secondhand tobacco smoke. Tobacco-related health disparities are not simply differences in the prevalence of tobacco product use between population groups; instead, the definition extends further to account for historical and societal factors that affect both differential exposure to tobacco and tobacco-related outcomes. Many communities disproportionately burdened by tobacco-related health disparities have notable strengths—such as social support infrastructure and social cohesion (Munford et al. 2020)—but poverty, systematic discrimination, and other social determinants of poor health have resulted in cumulative and compounding disadvantages over the lifespan of community members (Smith et al. 1997; Graham et al. 2006; Mitchell et al. 2019; The Lancet Healthy Longevity 2021). These disadvantages include differences in access to and quality of healthcare and access to other resources—such as education, transportation, healthy food, and safe jobs that provide living wages—that, if absent or compromised in quality or quantity, can lead to health disparities (Institute of Medicine 2003; National Cancer Institute [NCI] 2017; Stepanikova and Oates 2017).

The present report examines tobacco-related health disparities among minoritized racial and ethnic groups and sexual orientation and gender identity groups; persons with lower incomes; persons with lower educational attainment; occupational groups, including workers in manual labor and service sector jobs; persons with mental health conditions or substance use disorders; and persons who reside in rural areas or specific geographic regions. Since the 1998 Surgeon General’s report, scientific evidence has reinforced that inequitable policies, practices, and conditions disproportionately impact unique and intersectional groups (i.e., people with membership in two or more risk groups), exacerbating disparities in use of commercial tobacco products, exposure to secondhand tobacco smoke, and tobacco-related health outcomes (Cole 2009; NCI 2017). The present report is the first to document, in a single volume, patterns and trends related to (a) use of commercial tobacco products, (b) exposure to secondhand tobacco smoke, (c) exposure to marketing of tobacco products, and (d) tobacco-related health outcomes and the ways in which disparities in these outcomes are affected by intersectionality.

Although this report provides the most comprehensive examination of tobacco-related health disparities in a single Surgeon General’s report to date, it does not address every group subject to structural or social disadvantage or every aspect of tobacco-related health disparities. The report’s scope was limited by available data, scientific literature, coverage in previous and/or planned Surgeon General’s reports on tobacco product use, and practical considerations (e.g., feasibility and timeliness).

Moving forward, future reports of the Surgeon General might focus on additional topics, including but not limited to the rapidly evolving science on strategies to (a) advance health equity and (b) examine specific population groups in greater detail, such as persons with mental health conditions and/or substance use disorders; persons with physical and developmental disabilities; older adults; youth and young adults; specific occupational groups, including military service members and veterans; or people with a history of involvement with the criminal justice system.

### Purposes of this Report

This report serves dual purposes. First, it summarizes progress toward meeting the challenge of preventing and controlling commercial tobacco use and exposure to secondhand tobacco smoke among groups historically subjected to inequitable policies, practices, and conditions. It has been 25 years since the 1998 Surgeon General’s report documented that cigarette smoking is a persistent burden to African American, American Indian and Alaska Native, Asian American and Pacific Islander, and Hispanic persons (USDHHS 1998). In the preface of the 1998 report, then Surgeon General David Satcher stated, “I challenge federal and state agencies as well as researchers and practitioners in the social, behavioral, public health, clinical, and biomedical sciences to join me in the pursuit of effective strategies to prevent and control tobacco among racial/ethnic groups” (USDHHS, 1998, p. iv). Progress toward reducing tobacco use at the population level has occurred in the United States since 1998. Yet, improvements in tobacco-related policies, regulations, programs, research, surveillance, evaluation, health education, health systems, and clinical care and practices have not necessarily resulted in protections that are equitable across all population groups (NCI 2017) and across the places where members of these groups are born, live, learn, work, play, worship, grow, age, and seek healthcare (Centers for Disease Control and Prevention [CDC] 2015; USDHHS 2020; Office of Disease Prevention and Health Promotion n.d.a).

Second, this report provides a vision for eliminating tobacco-related health disparities while simultaneously advancing the goal of eliminating tobacco-related morbidity and mortality for all. Commercial tobacco product use, exposure to secondhand tobacco smoke, and subsequent health consequences are preventable; and most people who use tobacco products have been targeted for marketing of these products during youth and young adulthood—when they are especially vulnerable to both social influences and addiction (USDHHS 2012). Yet, it is important to distinguish between equality (concerned with equal opportunity and resources) and equity (concerned with ensuring full health potential for all groups). Equality is inferior to equity as a tobacco-control objective; the pursuit of tobacco-related health equity seeks not to attain the same unacceptable rates of tobacco use and exposure to secondhand tobacco smoke for all, but the “opportunity for everyone to reach their full health potential, regardless of any socially determined circumstance” (CDC 2015, p. 2, citing Whitehead and Dahlgren 2006). With this framing, this report builds on discussions of endgame strategies in previous Surgeon General reports (USDHHS 2014, 2020) by outlining key considerations to ensure that such strategies do not inadvertently introduce or exacerbate tobacco-related health disparities.

Finally, preparation of this report was guided by and responds to core principles emerging from the theory of social justice: knowledge and understanding, equal respect, and sharing power (Powers and Faden 2019; Wallerstein et al. 2019). Powers and Faden (2019) specify that knowledge and understanding are dependent on the institutional structures within which knowledge is generated. As such, institutions at the local, state, and federal levels have the capacity to create and transmit knowledge and understanding that increase access to information and equip people with skills and abilities across the lifespan to facilitate the achievement of the highest level of health for all people. It is important for institutions to guide practitioners and researchers to develop effective commercial tobacco prevention and control programs and to engage in research that has specific utility for and relevance to historically disadvantaged groups (Powers and Faden 2019), as assessed by members of these groups. Equal respect recognizes that everyone deserves to be treated with an equal moral standard and respect and that all people have intrinsic value (Powers and Faden 2019). As such, institutional documents, such as this report, play critical roles in acknowledging the inherent value of all people and advancing the public’s perception of their value in the world. Groups that have been socially and economically marginalized by society as a whole and targeted by the commercial tobacco industry have been subjected to decades of inequitable treatment and manipulative tactics that impact tobacco-related health consequences (Mialon 2020). This report summarizes the historical and societal factors that contribute to differences in health consequences along the tobacco use continuum. Finally, sharing power is critical to achieving tobacco-related health equity. The principle of sharing power is a continual commitment to eliminating power differences between impacted community members and institutions with the shared vision of a tobacco-free world (Wallerstein et al. 2019).

### Terminology About Population Groups

This is the first Surgeon General’s report on tobacco to consistently use “person-first” language that avoids the use of labels (i.e., “smoker,” “tobacco user”). The intent of person-first language is to humanize people as having a condition, characteristic, or circumstance; or engaging in a behavior—not being a condition (CDC 2022a).

Consistent with and building on previous Surgeon General reports, this report analyzes seven broad racial and ethnic groups established by the U.S. Office of Management and Budget (see Appendix 1.1): American Indian and Alaska Native, Asian, Black or African American, Hispanic or Latino, Native Hawaiian and Pacific Islander, White, and Multiple Race (Federal Register 1997). Additionally, throughout this report, careful consideration was applied to identifying diverse groups while not perpetuating “minoritization” of populations (Witherspoon et al. 2020; Flanagin et al. 2021) or flawed notions of race as a biological construct (Cooper and David 1986; Jones 2000). Race, ethnicity, and minority status are social constructs. Racialization is a social process that involves categorizing, marginalizing, or regarding according to race (Witzig 1996; Mendez and Spriggs 2008; Merriam-Webster n.d.). Ethnicity is a social construct that encompasses shared sociocultural factors and identities and reflects relations within ethnically defined groups and the society in which that group is situated (Ford and Harawa 2010). Minoritized refers to socially constructed groups who have been historically marginalized based on their racial, ethnic, sexual orientation, gender identity, or other social identity (Flanagin et al. 2021; National Institutes of Health [NIH] 2024). Numerous population groups across the world are defined by ancestry, history, language, shared cultures, religion, and other factors—the aggregation of which may be used for reporting and understanding underlying shared risks. However, these aggregated categories may not necessarily reflect important nuances within groups—including their tobacco product use behaviors—which may be masked when disaggregated data are not available. Further supporting the notion of race, ethnicity, and minority status as social constructs, the terms used to refer to these various groups change over time and may depend on the social, cultural, and political climates that govern how groups label themselves or are labeled by others. Relevant chapters of this report retain the original terminology used to refer to groups in published primary sources for accuracy in reporting results; however, contemporary terms are used to refer to groups when synthesizing the evidence across sources. Given these developments, the present report uses—where appropriate—the term minoritized population group in place of racial and ethnic minorities, sexual and gender minorities, people of color, and non-White. The terms used in the present report are expected to evolve as members of groups that have been marginalized continue to author and inform language used in scientific publications (Sotto-Santiago 2019).

Similarly, it is important to recognize diversity in sexual orientation and gender identity, including self-identification with straight, lesbian, gay, bisexual, transgender, queer, intersex, nonbinary, or other communities (Office of the Chief Statistician of the United States 2023). Data on the range of sexual orientations and gender identities are limited because of the lack of sexual orientation and gender identity inclusion in some federal, state, and local surveillance systems. This report synthesizes available data while acknowledging the need to improve measures of sexual orientation and gender identity, including transgender identity, to inform efforts to reduce health disparities among these populations. This report also acknowledges that terms referring to sexual orientation and gender identity have changed and continue to change over time; therefore, a multitude of terms may be relevant across studies.

### Terminology About Tobacco Products

Except where noted, the term tobacco in this report refers to commercial tobacco products and not to the sacred and traditional use of ceremonial tobacco by some American Indian communities (Unger et al. 2006; Keep It Sacred n.d.). Tobacco products refers to products made, containing, or derived from tobacco or containing nicotine from any source that are intended for human consumption, including but not limited to cigarettes (including menthol cigarettes), cigars (including premium cigars, little cigars, and cigarillos), waterpipe or hookah tobacco, pipe tobacco, electronic cigarettes (e-cigarettes), heated tobacco products, smokeless tobacco, and other oral tobacco or nicotine products without an approved therapeutic purpose. (See Appendix 1.1 for definitions that clarify terminology used in this report.) The landscape of tobacco products continues to rapidly diversify to include noncombustible, combustible, heated, electronic, and oral nicotine products, challenging surveillance systems and intervention efforts. Where nationally representative data are available, data on use are provided in Chapter 2 by tobacco product type. In general, unless otherwise specified, smoking refers to cigarette smoking, and people who smoke refers to people who smoke cigarettes.

### Influences on Tobacco Use and Interventions to Reduce Tobacco-Related Health Disparities

Tobacco-related health disparities have multifaceted influences that go beyond individual and intrapersonal factors, including the tobacco industry’s aggressive marketing and promotion of flavored and fragranced products, including mentholated products. Chapters that examine evidence about influences on tobacco product use and relevant protective interventions leverage a socioecological model that situates individual behaviors within a multilevel framework of interpersonal, community, or neighborhood environments and larger societal, systemic, and policy contexts (McLeroy et al. 1988; NCI 2017). Central to the report’s organization is the premise that individual use of commercial tobacco products is heavily influenced by the social determinants of health, defined as “conditions in the environments where people are born, live, learn, work, play, worship, and age that affect a wide range of health, functioning, and quality-of-life outcomes and risks” (Office of Disease Prevention and Health Promotion n.d.b).

Figure 1.1 Dynamics that can predispose, enable, and reinforce health disparities

This diagram presents the dynamics that can predispose, enable, and reinforce health disparities. On the left-hand side of this diagram, boxes representing “context” include the historical context and the power, ideology, and values of people and groups with decision-making authority. Context manifests as systems, institutions, policies, and funding or investment in research, interventions, and markets. On the right-hand side of the diagram are boxes representing “commercial drivers,” including the emergence of new markets, corporate innovations and expansion, and demand of growth and capital. Commercial drivers work through various channels, including marketing, supply, lobbying, and corporate citizenship. Arrows from both context (through these manifestations) and commercial drivers (through channels) point to a set of concentric circles in the center of the diagram. From the outer circle to the inner circle, these circles represent the differential impacts on (a) the environment, (b) communities, (c) people, and (d) health. Importantly, arrows emerge from the left-hand boxes (context) and extend to the right-hand boxes (commercial drivers), and vice versa, to show that these factors are mutually reinforcing.

This report builds on the socioecological model by acknowledging that multiple, multilevel social and commercial dynamics predispose, enable, and reinforce health disparities. Figure 1.1 presents how historical context, differential power structures, and the ideology and values of people and groups with decision-making authority manifest as systems, institutions, policies, and investment in research, interventions, and markets. Historical, political, and ideological contexts shape commercial drivers of health, including the emergence of new markets, corporate innovation and expansion, and demand of growth and capital, which Kickbusch and colleagues (2016) suggest manifests as product marketing, supply, lobbying, and corporate citizenship. Together, these social and commercial dynamics converge to create differential opportunities for health and, specific to this report, emerge as commercial tobacco-related health disparities. Leveraging this model, this report concludes by identifying multilevel opportunities to advance commercial tobacco-related health equity—fair, equitable, and just opportunities and conditions for all people to live a healthy life, free from commercial tobacco-related disease, disability, and death (CDC 2015).

## Organization of the Report

This report includes eight chapters. The current chapter (“Introduction, Summary, Conclusions, and History of Tobacco-Related Health Disparities”) introduces the report and its framework and presents major conclusions and the conclusions from each chapter. It concludes with a review of the history of tobacco-related health disparities in the United States and provides context for understanding such disparities in the changing landscape of tobacco prevention and control. Chapter 2 (“Disparities in Tobacco Use and Exposure to Secondhand Tobacco Smoke”) uses epidemiological data to document the persistence of a high prevalence of commercial tobacco use among certain segments of the population and the greater exposure to secondhand smoke that affects some disaggregated population groups. Chapter 3 (“Physiological, Chemosensory, and Genetic Influences of Menthol and Other Flavors in Tobacco Products”) summarizes the current knowledge about the chemosensory and physiological mechanisms through which menthol and other flavor chemicals in tobacco products act, and the genetic factors that may influence these mechanisms and may contribute to flavored tobacco product use disparities. This research may help to explain the appeal of flavored tobacco products that elicit multisensory experiences among youth, women, and people within certain racial and ethnic groups.

Chapter 4 (“Social and Environmental Influences on Tobacco-Related Health Disparities”) and Chapter 5 (“Tobacco Industry Influences on Tobacco-Related Health Disparities”) examine the social, environmental, and industry factors that influence tobacco-related health disparities in a broader set of populations than were reported in previous Surgeon General’s reports, including sexual orientation and gender identity groups, socioeconomically disadvantaged populations, and persons with behavioral health conditions. Chapter 6 (“Disparities in Smoking-Caused Disease Outcomes and Smoking-Attributable Mortality”) describes disparities in incidence and mortality due to smoking-caused diseases—including cancer, COPD, and cardiovascular disease—and in smoking- and secondhand-smoke-attributable mortality using various analytic and modeling techniques.

Chapter 7 (“Promising Interventions to Reduce Tobacco-Related Health Disparities”) uses a socioecological perspective to highlight opportunities to address tobacco-related health disparities at multiple levels, such as implementing smokefree policies; regulating tobacco products, including reducing nicotine levels; eliminating flavored tobacco products; enacting policies to reduce the supply of and demand for tobacco, including regulating where retailers are located; and regulating commercial tobacco pricing through taxation and other price-related strategies. The chapter also reviews evidence about mass media campaigns; interventions, policies, and practices in organizational and institutional settings, such as schools, healthcare systems, and workplaces; interpersonal interventions; and individual interventions. Chapter 8 (“A Vision for Eliminating Commercial Tobacco-Related Health Disparities”) outlines broad strategies to address tobacco-related health disparities moving forward.

## Preparation of the Report

This Surgeon General’s report was prepared by the Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, CDC, which is part of USDHHS. This report was compiled using a longstanding, balanced, and comprehensive process designed to safeguard scientific rigor and practical relevance from influences that could adversely affect impartiality (King et al. 2018). This process helps to ensure that the report’s conclusions are defined by the scientific evidence, rather than by the opinions of the authors and editors. In brief, an external editorial team of senior scientists selected 58 experts for their knowledge of specific topics to write the initial drafts of the chapters. These contributions, which are presented as Chapters 2–7, were evaluated by 21 peer reviewers. After this initial stage of peer review, 13 senior scientists and other experts—primarily external to CDC—examined the scientific integrity of the entire manuscript as part of a second stage of peer review. After each round of peer review, the report’s scientific editors revised each draft based on reviewers’ comments. Chapter 8, written by the editorial team after Chapters 1–7 had completed the second stage of peer review, outlines broad strategies to accelerate progress in eliminating tobacco-related health disparities.

Subsequently, the report was reviewed by various institutes and agencies in the U.S. government, including those in USDHHS. Throughout the review process, the content of each chapter was revised to include studies and information that were not available when the chapters were first drafted; updates were made until shortly before the report was submitted for publication. These updates are intended to reflect the full scope of identified evidence, including new findings that confirm, refute, or refine the content in the initial drafts at the time the report was submitted for publication. However, updates made during the review process may not capture all recently published findings, since systematic reviews could not be conducted again so close to publication date. Conclusions are based on the preponderance and quality of scientific evidence available at the time of publication.

## Scientific Basis of the Report

The statements and conclusions throughout this report are based on an extensive review of the existing scientific literature and analyses of new data from various sources. The report primarily cites peer-reviewed journal articles, including reviews that integrate findings from numerous studies and books that were published between 1998 and 2021, the period after the last Surgeon General’s report on the topic of tobacco-related health disparities among population groups (USDHHS 1998). The report focuses primarily on tobacco-related health disparities among U.S. population groups in the context of adults because this is the population for which the preponderance of scientific literature exists on this topic. However, data on youth and young adults are presented where available given the importance of continuing to work to prevent and reduce the use of all forms of tobacco products among young people.

This report also refers, on occasion, to unpublished research, such as presentations at professional meetings, personal communications from researchers, and information available in various media. These references are used when acknowledged by the chapter authors, editors, and reviewers as being scientifically valid and reliable and a critical addition to the emerging literature on a topic. Throughout the writing and review process, highest priority was given to peer-reviewed scientific research. Following the model established in 1964, this report includes comprehensive compilations of the evidence on its topic of focus. The evidence was analyzed to identify causal associations according to enunciated principles as outlined in Chapter 3 of the 1964 report, including

- “Consistency of the association,
- Strength of the association,
- Specificity of the association,
- Temporal relationship of the association, and
- Coherence of the association” (U.S. Department of Health, Education, and Welfare [USDHEW] 1964, p. 20).

In the 2004 Surgeon General’s report (USDHHS 2004), the framework for interpreting evidence on smoking and health was revisited in depth for the first time since the 1964 report. The 2004 report provided a four-level hierarchy of categories for interpreting evidence, and this current report follows the same model:

1. “Evidence is sufficient to infer a causal relationship.
2. Evidence is suggestive but not sufficient to infer a causal relationship.
3. Evidence is inadequate to infer the presence or absence of a causal relationship (which encompasses evidence that is sparse, of poor quality, or conflicting).
4. Evidence is suggestive of no causal relationship” (USDHHS 2004, p. 18).

The categories acknowledge that evidence can be “suggestive but not sufficient” to infer a causal relationship, and the categories allow for evidence that is “suggestive of no causal relationship.” Consistent with past Surgeon General’s reports on tobacco use, conclusions are not limited to causal determinations and frequently include recommendations for research, policies, or other actions.

Similar to previous reports, this report assesses evidence from studies using a variety of measures and levels of analysis, including studies of main effects, interactions, stratified samples, and nested designs. The report also considers policy analysis studies, which vary greatly in their approaches and applications of theoretical frameworks. This consideration of complex and varied methodologies, as well as the fact that effects change strength and direction by population groups, challenged the development of four-level hierarchical causal conclusions that encompass all racial and ethnic groups and other population groups.

## Major Conclusions

1. Despite strong progress in reducing tobacco use at the population level, disparities in use persist by race and ethnicity, level of income, level of education, sexual orientation, gender identity, type of occupation, geography, and behavioral health status. Exposure to secondhand tobacco smoke remains disproportionately higher among Black people than among people in other racial and ethnic groups, youth than among adults, and people from lower socioeconomic backgrounds than among those from higher socioeconomic backgrounds.
2. Tobacco-related health disparities are a social injustice, in addition to an economic and health burden. Addressing disparities requires reflection on the complex history of the commercialization of tobacco and both past and present-day experiences of racism, discrimination, and targeted marketing by the tobacco industry.
3. Social, structural, and commercial determinants of health—such as persistent poverty and inequitable economic and social conditions—lead to inequitable opportunities for living a life free from tobacco-related death and disease. Racism, discrimination, and targeted marketing by the tobacco industry; geographic disparities in evidence-based policy protections; preemptive laws that thwart communities from protecting their residents’ health and safety; and financial and other structural barriers to accessing cessation treatments also drive tobacco-related health disparities.
4. The tobacco industry has designed, engineered, and marketed menthol cigarettes and other tobacco products that deliver multisensory flavor experiences which increase the likelihood of tobacco initiation, addiction, and sustained use. Policies that restrict the availability of menthol cigarettes can reduce smoking initiation and prevalence among adolescents, young adults, Black people, and other population groups that have disproportionately higher use of menthol cigarettes.
5. For decades, the tobacco industry has targeted its products and marketing to specific groups, including through concentrated marketing in neighborhoods with greater percentages of Black people, Hispanic people, and residents with lower incomes. Tobacco companies employ multiple tactics to undermine tobacco prevention and control efforts and enhance their corporate image.
6. Cigarette smoking remains a major cause of death and disease—including cancer, cardiovascular disease, and chronic obstructive pulmonary disease—among all racial and ethnic groups. More than 490,000 deaths attributable to cigarette smoking and exposure to secondhand tobacco smoke are estimated to occur in the United States each year—about one in five of all deaths in the United States. This includes more than 473,000 deaths attributable to cigarette smoking and more than 19,000 deaths attributable to exposure to secondhand tobacco smoke.
7. Each year, more than 50,000 Black adults, 15,000 Hispanic adults, and 400,000 White adults are estimated to die from causes attributable to cigarette smoking. Despite large absolute differences in the numbers of smoking-attributable deaths by race and ethnicity, smoking accounts for a similar proportion of deaths among non-Hispanic Black (18%) and non-Hispanic White (20%) people and for approximately 10% of deaths among Hispanic people.
8. Data from surveillance and intervention research are limited for many groups known to be at high risk for tobacco use, exposure to secondhand tobacco smoke, and targeted marketing by the tobacco industry. While protecting recent gains in measurement, further efforts are warranted to assess structural and social determinants of health across the lifespan, disaggregate data, oversample disparate populations, and increase understanding of the impact of interventions on tobacco-related health disparities.
9. Endgame efforts to eliminate tobacco-related disease, disability, and death should create opportunities and conditions for all people to live healthy lives that are free from commercial tobacco. Interventions designed to reduce the use of tobacco products and the influences of the tobacco industry on society should accompany efforts to remove the underlying social, structural, commercial, and political drivers of health inequities.
10. In addition to social and structural interventions, a comprehensive and multilevel effort toward health equity must include a combination of complementary approaches to reduce the affordability, accessibility, appeal, and addictiveness of tobacco products; eliminate exposure to secondhand tobacco smoke; conduct high-impact media campaigns; and promote barrier-free access to cessation support with broad reach to disparate populations. Strategies should be implemented equitably and with fidelity in all jurisdictions.

## Chapter Conclusions

### Chapter 1 Introduction, Overview, Conclusions, and History of Tobacco-Related Health Disparities

1. The complex and centuries-long historical context of tobacco commercialization is a foundational driver of present-day tobacco-related health disparities.
2. For decades, tobacco-related health disparities have not received the necessary investments of research, time, and resources.
3. Poverty, racism, and discrimination are important and long-standing social and structural determinants that marginalize minoritized racial, ethnic, gender identity, and sexual orientation groups and provide the context in which tobacco-related health disparities have occurred for many decades.
4. Not all vulnerable groups are disparate groups. A disparate group is not only vulnerable to tobacco use but may also face social determinants of poor health (e.g., poverty), cumulative indicators of social disadvantage across the lifespan, and historical injustices (e.g., discrimination, colonization).
5. Tobacco industry marketing has historically targeted minoritized racial and ethnic groups and minoritized sexual orientation and gender identity groups.
6. States and localities have helped to build momentum to enact and implement policies that prohibit the sale of menthol cigarettes and other flavored tobacco products.

### Chapter 2 Disparities in Tobacco Use and Exposure to Secondhand Tobacco Smoke

1. Racial and ethnic disparities in cigarette smoking have persisted since 2000, with prevalence remaining highest among American Indian and Alaska Native adults. Frequency, type, and amount of tobacco use; long-term cessation success; and patterns of use across the life course also differ by race and ethnicity. Within aggregate racial and ethnic groupings, disparities in tobacco use vary by ethnic group, nativity, and acculturation in the United States.
2. Disparities in cigarette smoking by educational attainment have notably widened in the past 50 years; the prevalence of smoking is substantially higher among people without college diplomas than it is among those with college diplomas.
3. The prevalence of tobacco use is higher among adults living in poverty than it is among adults living at or above the poverty level. Disparities in cigarette smoking by poverty status have persisted over four decades, and these differences remain when looking at the prevalence of smoking by poverty status and other demographic characteristics, including sex, race, ethnicity, and sexual orientation.
4. The prevalence of tobacco use is higher overall among youth and adults who identify as gay, lesbian, and bisexual than it is among youth and adults who identify as heterosexual, but the prevalence of tobacco use varies by different populations, such as gay, lesbian, or bisexual populations, and by specific tobacco products. Increased availability and improvements in the measures to assess sexual orientation and gender identity in federal, state, and local surveillance systems will assist efforts to better address disparities among these populations.
5. The prevalence of ever and current smoking is higher among manual labor and service workers than it is among workers in other occupational groups. Conversely, the prevalence of cigarette smoking cessation is lower among manual labor and service workers than it is among workers in other occupational groups. Accommodation and food service, construction, and mining are the occupation groups with the highest prevalence of current cigarette smoking. These settings may warrant greater support for smoking cessation interventions.
6. The prevalence of tobacco use is generally higher in the South and Midwest than it is in other regions of the United States. Additionally, the prevalence of cigarette and smokeless tobacco use is higher among people living in rural areas than it is among people living in urban areas.
7. People living with any mental health condition or substance use disorder are at increased risk of tobacco use. The intersection of mental health, substance use, and sociodemographic characteristics—such as age, sex, race and ethnicity, sexual orientation, and socioeconomic status—adds to the risk of tobacco use.
8. Despite progress in the adoption of smokefree policies, the prevalence of exposure to secondhand tobacco smoke remains disproportionately high among (a) children compared with adults, (b) non-smoking African American youth and adults compared with nonsmoking White or Mexican American youth and adults, (c) families in lower income groups compared with families in higher income groups, and (d) adults without college diplomas compared with adults with college diplomas. The magnitude of these disparities has increased since 2000.

### Chapter 3 Physiological, Chemosensory, and Genetic Influences of Flavors and Menthol in Tobacco Products

1. The evidence is sufficient to infer that some natural and synthetic chemicals and flavorants that are added to tobacco products have pharmacological effects; act as cues and reinforcers; and, in some cases, act centrally to modulate the brain reward circuitry.
2. Natural and synthetic chemicals and flavorants added to tobacco products elicit multisensory experiences, including odorant (olfactory) effects; basic taste perceptions (e.g., sweet, bitter); and somatosensory effects, such as cooling.
3. Sweeteners are used in tobacco products to mask aversive tastes and have been detected at high levels in certain oral tobacco products. Sweet taste appeals more to young people than it does to older people.
4. Smoking status; use of flavored tobacco products; and related disparities by age, gender, and race and ethnicity result from multilevel influences. Targeted marketing, societal and cultural factors, and genetic variations that affect underlying chemosensory and physiological mechanisms result in differences in the appeal of and ability to perceive certain flavor qualities, such as bitter taste.
5. Determinations that flavorants are “generally recognized as safe” for use in foods are not applicable to the inhalation of tobacco products. These ingredients, when inhaled, may be directly toxic to the lungs or could result in higher absorption of toxicants. Commonly used natural and synthetic chemicals and flavorants may be safe to ingest in foods but might be harmful when inhaled.
6. Animal studies suggest that menthol and sweeteners influence nicotine uptake. Menthol and other flavorants, such as farnesene and farnesol, directly affect the dopaminergic reward circuitry and may potentiate the addictive effects of nicotine.
7. Natural and synthetic cooling agents that have been found in some tobacco products (a) act on different parts of the oral cavity and the respiratory system to enhance the experience of smoking or use of other tobacco products and (b) can mimic the pharmacological and somatosensory effects of menthol but may not have a distinguishing taste or odor. Cooling agents, even those without a taste or odor, have the potential to increase the appeal of tobacco products, facilitate their use, and contribute to tobacco-related health disparities. Comprehensive flavor policies that account for these agents will better protect public health.
8. Genetic studies provide suggestive evidence that variations in genes involved in sensory mechanisms and taste perception may influence menthol smoking in youth, women, and some minoritized racial and ethnic groups. The emerging science on the role of genes in flavor experiences should be understood in context with multilevel commercial, societal, and cultural factors that influence tobacco-related health disparities.

### Chapter 4 Social and Environmental Influences on Tobacco-Related Health Disparities

1. Tobacco use among peer groups increases the likelihood of smoking initiation for White, Black, and Hispanic adolescents.
2. For adolescents, participating in extracurricular activities or feeling a sense of belonging at school can reduce the likelihood of cigarette smoking initiation. However, Black and Hispanic adolescents report lower school connectedness than White adolescents, which may increase the likelihood of smoking initiation.
3. As Asian American and Hispanic or Latino immigrants undergo acculturation to life in the United States, there is a greater risk of cigarette smoking among women and a reduced risk of smoking among men.
4. Inequitable smokefree protections for people living in multi-unit housing contribute to disparities in exposure to secondhand tobacco smoke.
5. Although smokefree policies in the workplace can reduce the use of tobacco products and encourage quitting, not everyone is evenly protected by these policies. Work-related stress and exposure to occupational hazards are linked to smoking initiation and difficulty quitting smoking.
6. Disparities in utilization of evidence-based cessation treatments exist, including by race and ethnicity, socioeconomic status, and health insurance status. Disparities persist in having received advice to quit smoking from a healthcare professional, particularly among minoritized racial and ethnic groups and lower socioeconomic status groups.

### Chapter 5 Tobacco Industry Influences on Tobacco-Related Health Disparities

1. Tobacco marketing in general and marketing for menthol cigarettes in particular are more prevalent in neighborhoods with greater percentages of African American residents or of residents with lower incomes compared with neighborhoods with lower percentages of African American residents or of residents with higher incomes.
2. Communities with high concentrations of people from diverse racial and ethnic population groups, residents with lower income, and adolescents tend to have greater availability of cheaper tobacco products, including menthol cigarettes, that are widely available at local retailers.
3. Members of the LGBTQI+ community and people with lower socioeconomic status are more likely to receive and use a coupon or price discount code to purchase tobacco products compared with their heterosexual and cisgender counterparts and those of higher socioeconomic status. Use of coupons appears to increase the likelihood of tobacco initiation among people who have never used tobacco and to reduce the likelihood of quitting among people who use tobacco.
4. Seismic shifts in the media environment have produced rapid changes in marketing strategies for commercial tobacco. Tactics such as influencer marketing that allow more focused and segmented targeting have the potential to exacerbate existing disparities in tobacco initiation and use.
5. The tobacco industry continues to employ political, legal, economic, corporate social responsibility, and community tactics to enhance its image among the communities it targets in marketing—including minoritized racial and ethnic groups and sexual orientation and gender identity groups that are subject to tobacco-related health disparities—and/or to counter efforts that would benefit public health and advance health equity.

### Chapter 6 Disparities in Smoking-Caused Disease Outcomes and Smoking-Attributable Mortality

1. Smoking is the primary cause of lung and bronchus cancers—the leading cause of cancer death in the United States. Recent declines in the lung and bronchus cancer death rate have occurred among both men and women. Among men, the death rate for lung and bronchus cancer is highest among Black men, followed by White men, American Indian and Alaska Native men, Asian and Pacific Islander men, and Hispanic men. Among women, the death rate for lung and bronchus cancer is highest among White women, followed by American Indian and Alaska Native women, Black women, Asian and Pacific Islander women, and Hispanic women.
2. Cigarette smoking is a primary cause of COPD and the primary risk factor for the worsening of COPD. The overall prevalence of COPD is highest among American Indian and Alaska Native adults and lowest among Asian adults. There is a clear socioeconomic gradient for COPD prevalence and mortality, with higher prevalence and mortality occurring among people with lower income and lower educational attainment.
3. Cigarette smoking and exposure to secondhand tobacco smoke have adverse effects on overall cardiovascular health and cause cardiovascular disease. Among men, the prevalence of cardiovascular disease in 2017–2020 was highest among non-Hispanic Black (11.3%) and non-Hispanic White (11.3%) men, followed by Hispanic (8.7%) and non-Hispanic Asian (6.9%) men. Among women, the prevalence of cardiovascular disease was highest among non-Hispanic Black women (11.1%), followed by non-Hispanic White (9.2%), Hispanic (8.4%), and non-Hispanic Asian (4.9%) women.
4. From 2010 to 2018, an estimated 4.26 million smoking-attributable deaths occurred among non-Hispanic Black, Hispanic, and non-Hispanic White adults in the United States. Among those groups, at least 473,000 cigarette smoking-attributable deaths are estimated to have occurred each year. The number of smoking-attributable deaths is likely underestimated due to insufficient data among additional racial and ethnic groups.
5. Smoking causes about 1 in 5 deaths among non-Hispanic White and non-Hispanic Black people and about 1 in 10 deaths among Hispanic people.
6. An estimated 19,600 deaths attributable to exposure to secondhand tobacco smoke occurred among non-smoking people in the United States based on data from 2019 and 2020. Deaths attributable to exposure to secondhand tobacco smoke have declined considerably since 2006, but this is largely due to the declines in death observed among non-Hispanic White people. Declines occurred at lower rates during this period among non-Hispanic Black, Hispanic, and other non-Hispanic racial groups.
7. Simulation models can be useful tools to project the potential effects of large-scale interventions on smoking-attributable morbidity and mortality and on disparities in tobacco use across various populations. Future modeling efforts would benefit from (a) more detailed data on patterns of smoking and the use of noncigarette tobacco products; and (b) more robust data for racial and ethnic groups; minoritized sexual orientation and gender identity groups; urban and rural communities; and other focused populations.
8. Aggregation of data on tobacco product use, disease incidence, and mortality may mask disparities within population groups, such as within Asian American and Native Hawaiian and Other Pacific Islander groups. Disaggregation of data reporting and oversampling among disparate populations will foster greater understanding of tobacco-related health disparities.

### Chapter 7 Promising Interventions to Reduce Tobacco-Related Health Disparities

1. Preemption at the federal and state levels can pose a significant obstacle for pursuing innovative policies to advance tobacco-related health equity and limits the ability of population groups that experience disparities to benefit from proven tobacco control interventions.
2. The evidence is sufficient to infer that comprehensive smokefree laws that apply to all indoor areas of public places and workplaces, including casinos, as well as smokefree policies for multi-unit housing would reduce disparities in smokefree protections and reduce exposure to secondhand tobacco smoke if fully and equitably adopted, implemented, and enforced.
3. Reducing nicotine in cigarettes and other combustible tobacco products to minimally addictive or nonaddictive levels should reduce tobacco use among many population groups experiencing tobacco-related disparities.
4. The evidence is sufficient to infer that policies that prohibit the sale of flavored tobacco products reduce sales of tobacco products and can reduce tobacco use. Eliminating the sale of flavored tobacco products, including flavored cigars, should also reduce tobacco use among groups experiencing disparities in tobacco use, especially if the policies are comprehensive and equitably implemented.
5. The evidence is sufficient to infer that policies that prohibit the sale of menthol cigarettes reduce the sale of cigarettes and increase smoking cessation. Given the disproportionate burden of menthol cigarette use among some population groups, removing menthol cigarettes from the marketplace should also reduce disparities in tobacco initiation, nicotine dependence, cessation success, and tobacco-related health outcomes, especially if policies are comprehensive and equitably implemented.
6. Policies that regulate the location of and reduce the number of tobacco retailers in neighborhoods with a high proportion of lower income, Black, or Hispanic people could help reduce disparities in retailer density, exposure to tobacco product advertisements and displays, and sales and use of tobacco products.
7. The evidence is sufficient to conclude that increases in tobacco product prices will reduce tobacco use to a greater extent among people of lower SES than they do for people of higher SES. Youth are especially price-sensitive, and price increases could help reduce tobacco use among people from all population groups at the age when they are most likely to begin smoking.
8. The evidence is sufficient to infer that quitlines can increase access to cessation treatments among population groups affected by tobacco-related disparities, particularly when quitline promotion and services are developed, delivered, and evaluated with attention to their reach and relevance to these groups.
9. The evidence is sufficient to infer that mass media countermarketing campaigns are effective at increasing quit attempts among many population groups affected by tobacco-related disparities, particularly when designed and delivered with attention to reach and relevance to these groups. However, it remains unclear if campaigns designed specifically for a single focus population are more or less effective at decreasing disparities in initiation or cessation than campaigns designed for multiple focus populations.
10. Cultural tailoring of cessation interventions (versus nontailored interventions) shows promise for increasing quitting readiness and quit attempts among African American adults and for increasing successful quitting among Asian American adults, though tailoring may not increase long-term cessation among African American adults.
11. The evidence is suggestive, but not sufficient, to conclude that incentives paired with cessation treatments increase smoking cessation among populations with lower socioeconomic status.
12. As additional research is undertaken to advance understanding of the impacts of tobacco control interventions—including cessation, media campaign, and policy interventions—on health disparities, extra considerations should be taken to ensure that such research is designed to allow for the examination of the impact of interventions among populations experiencing health disparities (e.g., ensuring enrollment of diverse populations, oversampling of population groups, attention to sample recruitment and retention, and community-engaged participatory research approaches).

## History of Tobacco-Related Health Disparities

Addressing tobacco-related health disparities requires a reflection on the complex history of the commercialization of tobacco. This section provides an overview of the history of tobacco-related health disparities and context for understanding some patterns of disparities in the United States. Table 1A.1 in Appendix 1.2 includes a chronology of key events related to tobacco-related health disparities.

### A Complex History of Tobacco Commercialization

The centuries-long historical context of tobacco commercialization is a foundational driver of present-day tobacco-related health disparities in the United States, as well as intergenerational socioeconomic disparities. When Europeans arrived in the Americas, tobacco had been cultivated for centuries across much of North and South America by Indigenous peoples for spiritual and ceremonial purposes; some of these practices endure today (Hodge 1910; Sherman 1972). Colonization resulted in the forced removal of Indigenous people from their lands, and colonial landowners repurposed ceremonial tobacco into a commercial product grown on those lands (Pérez-Stable and Webb Hooper 2021; Nez Henderson et al. 2022).

Postcolonial policies further disrupted these traditional practices. Beginning in the late 19th century, federal laws (e.g., Code of Indian Offenses [1883], Dawes Act of 1887) had the cumulative effect of prohibiting Indigenous people from ceremonial uses of tobacco. For example, in 1883, the Code of Indian Offenses outlawed many traditional American Indian religious practices that incorporated ceremonial tobacco, including ghost and sun dances, the use of medicine men, funeral practices, and ritualized gift-giving ceremonies (Nez Henderson et al. 2022; National Geographic n.d.). Additionally, the Dawes Act of 1887 reduced Indigenous lands by 65% and allotted the remaining land in parcels to Indigenous families. Allotted land was often barren and unsuitable for growing tobacco, minimizing the supply of traditional tobacco (Keep It Sacred n.d.; National Archives n.d.). House Concurrent Resolution 108 (1953) and other U.S. policies through 1968 sought to further abolish tribes, relocate Indigenous people, and sell their land. This displacement resulted in the relocation of many Indigenous people to urban areas and termination of federal obligations to tribes—including federal aid, services, and protections—and further challenged the cultivation of traditional tobacco (Native Voices 1953). Although practices involving traditional tobacco were outlawed, commercial tobacco use was legal (Nez Henderson et al. 2022). With the intent to keep cultural practices alive, some American Indian communities began to substitute commercial tobacco products for traditionally grown tobacco at ceremonies (Nez Henderson et al. 2022). Not until 1978 did Indigenous people formally regain their ability to exercise their traditional religious practices without penalty through the passage of the American Indian Religious Freedom Act (American Indian Religious Freedom Act of 1978 1978; American Indian Religious Freedom Act Amendments of 1994 1994; Nez Henderson et al. 2022).

The sacred and traditional meanings of ceremonial tobacco endure today for many American Indian communities and are an example of the resilience of Indigenous communities (Nez Henderson et al. 2022). Distinguishing between ceremonial tobacco and commercial tobacco products is important to enhance efforts to address present-day disparities in commercial tobacco use among Indigenous Americans (USDHHS 1998).

As documented in the 1998 Surgeon General’s report, the commercialization of tobacco also has historical ties to the enslavement of people of African descent (USDHHS 1998). Prior to the first recorded landing of African people in the United States in 1619, White people imprisoned in Europe were brought to the colonies to cultivate tobacco as a form of employment in exchange for shorter sentences (Encyclopedia Virginia 1737). However, as demand for commercial tobacco grew in Europe, colonial land-owners sought a larger and less expensive labor force, often turning to African indentured servants and later to the enslavement of African people and their descendants (Kulikoff 1986). After the Emancipation Proclamation was issued in 1863 and into the early 1900s, the “dirtiest, unhealthiest, and lowest paying jobs” in tobacco factories were performed by Black women in the United States (USDHHS 1998, p. 208, citing Jones 1984). At the time, White women were viewed as the only group to have the manual dexterity to operate the machines in these facilities; it was also regarded as socially unacceptable for Black men and women to work alongside White women. Thus, factory workers who were Black were relegated to less skilled and lower paying jobs (USDHHS 1998). By the early 20th century, the tobacco industry began relying on Black people, not only as laborers but also as consumers. Advertising and product design targeting Black people, particularly for menthol cigarettes, increased in the 1950s (Robinson et al. 1992; Gardiner 2004).

Native Hawaiian and other Pacific Islander people have also been negatively impacted by commercial tobacco. The introduction of commercial tobacco products into the Pacific region and the use of commercial tobacco as payment for products and services in this region have had lasting impacts on the health of Native Hawaiian people and other Pacific Islander people (Marshall 2013; CDC 2022b). As documented in Chapter 5, the tobacco industry has viewed Native Hawaiian people as an important market for menthol cigarettes since at least the 1980s; approximately three in four Native Hawaiian and other Pacific Islander adults who smoke use menthol cigarettes (see Chapter 2). Additionally, Native Hawaiian people who engage in lower intensity smoking behaviors may face disproportionate health risks. Specifically, data from the Multiethnic Cohort Study showed that Native Hawaiian people and Black people had a higher risk for lung cancer than White, Japanese American, and Hispanic or Latino people who smoked a similar number of cigarettes; disparities more pronounced among people who smoked 10 cigarettes per day than among those who smoked 35 cigarettes per day (Haiman et al. 2006; Stram et al. 2019).

Today, cigarette smoking is higher among American Indian and Alaska Native youth and adults than it is among any other racial and ethnic group in the United States, and menthol cigarette smoking is highest among Black adults, followed by Native Hawaiian and other Pacific Islander adults (see Chapter 2). The intergenerational consequences of these and other historical factors—such as housing discrimination and residential segregation and inequities in education, employment opportunities, wages, and access to quality health care—contribute to present-day socioeconomic and health disparities, including tobacco-related health disparities (Hood et al. 2016; Pérez-Stable and Webb Hooper 2021; Swope et al. 2022). Acknowledging the historical origins of these inequities can reduce the potential for impacted communities to be unfairly blamed for present-day experiences of disparities. Chapter 5 documents present-day examples of targeted marketing by the tobacco industry to specific groups, including but not limited to American Indian and Alaska Native, Black/African American, and Native Hawaiian and Pacific Islander people.

#### Tobacco-Related Health Disparities and Surgeon General’s Reports

Previous Surgeon General’s reports provide a historical review of efforts to reduce the prevalence of smoking in the United States (USDHHS 2000b). The first Surgeon General’s Report on smoking and health, released in 1964, was based on epidemiologic studies that helped establish a causal relationship between smoking and chronic diseases, such as cancer. However, most studies investigating the impact of smoking were limited to White men. Thus, the report concluded that cigarette smoking is a significant cause of overall mortality, causes lung and larynx cancer in men, and is a probable cause of lung cancer in women. Few studies at the time reported data on women and other population groups defined by age, race, ethnicity, geography, occupation, income level, educational attainment, and sexual orientation or gender identity. The 1980 Surgeon General’s Report, The Health Consequences of Smoking for Women, definitively concluded that women experienced the same health outcomes from smoking as did men (USDHHS 1980).

Later, the 1998 Surgeon General’s report, Tobacco Use Among U.S. Racial/Ethnic Minority Groups—African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics: A Report of the Surgeon General, became the first to highlight the associations between tobacco use among racial and ethnic groups and intersections with sex, income, and education (USDHHS 1998). The report issued the first call to action to prevent unnecessary disease, death, and disability caused by tobacco use, exposure to secondhand tobacco smoke, and exposure to commercial tobacco products among racial and ethnic groups.

Before the release of the 1998 Surgeon General’s report, scientific data were limited, and no comprehensive synthesis of data was available to inform the development of effective tobacco prevention and control programs or guide future research related to tobacco-related health disparities among U.S. racial groups. The 1998 report recognized that America was becoming more racially and ethnically diverse and that the future health of all American people would depend on the nation’s capacity to eliminate tobacco-related health disparities (USDHHS 1998).

The 1998 Surgeon General’s report was also the first to provide the historical context in which tobacco use influences the economic, spiritual, and social lives of Black or African American, American Indian and Alaska Native, Asian American, Native Hawaiian and Other Pacific Islander, and Hispanic or Latino people. This historical context is critical to understanding how tobacco—as a cash crop, commercial product, and ceremonial artifact—has been embedded into certain societies, communities, and neighborhoods.

Subsequent to the 1998 report, the 2000 Surgeon General’s report, Reducing Tobacco Use, identified the elimination of tobacco-related health disparities as a top priority and encouraged researchers, practitioners, and advocates to continue to address this significant challenge (USDHHS 2000b). In 2017, NCI published Tobacco Control Monograph 22, A Socioecological Approach to Addressing Tobacco-Related Health Disparities, which was the first major report published by the federal government since the 1998 Surgeon General’s report to highlight tobacco-related health disparities in the United States. The monograph documented continued disparities attributable to multilevel factors, the need for enhanced and additional interventions, and the need for research and improved surveillance (NCI 2017). Finally, the 2014 and 2020 Surgeon General’s reports documented large disparities in tobacco use and in key indicators of smoking cessation by race and ethnicity, geography, poverty status, and educational attainment (USDHHS 2014, 2020).

#### Defining Tobacco-Related Health Disparities

No comprehensive definition of tobacco-related health disparities existed prior to the early 2000s. The 1998 Surgeon General’s report (USDHHS 1998) and Healthy People 2010 (USDHHS 2000a) provided the impetus for developing a clear definition for tobacco-related health disparities. Healthy People 2010 established two main goals: (1) enhance life expectancy and quality of life and (2) eliminate health disparities between different segments of the U.S. population (USDHHS 2000a; National Center for Health Statistics 2012). Healthy People 2010 also included a focus on eliminating differences in tobacco use and subsequent tobacco-related outcomes by sex, racial and ethnic group, education level, income level, disability status, geographic location, and sexual orientation status (USDHHS 2000a; National Center for Health Statistics 2012). These objectives focused on tobacco use, smoking cessation and the availability of cessation treatment programs, exposure to secondhand smoke, attitudes of adolescents toward smoking, and tobacco control laws.

The National Conference on Tobacco and Health Disparities: Forging a National Research Agenda to Reduce Tobacco-Related Health Disparities (Fagan et al. 2004) met in 2002 to identify gaps in knowledge and develop a research agenda to eliminate tobacco-related health disparities (Fagan et al. 2004; King 2005). Tobacco-Related health disparities were defined at the conference as “differences in patterns, prevention, and treatment of tobacco use; the risk, incidence, morbidity, mortality, and burden of tobacco-related illness that exist among specific population groups in the United States; and related differences in capacity and infrastructure, access to resources, and environmental tobacco smoke exposure” (Fagan et al. 2004, p. 211).

Fagan and colleagues (2007) later modified the definition to capture more details about the patterns of tobacco use that affect prevention and treatment—that is, differences in the tobacco use continuum: exposure to, or being around other peoples’ tobacco products; exposure to secondhand smoke; marketing; initiation; current use; number of cigarettes smoked per day; quitting or treatment; relapse; and health consequences—and differences in capacity, infrastructure, and access to resources were updated to include differences in access to care, quality of healthcare, socioeconomic indicators that affect healthcare, and psychosocial and environmental resources. Underlying this definition is an acknowledgment that tobacco-related health disparities are not simply differences between groups. Many people are born into groups whose members have historically been poor, marginalized, or subjected to systematic discrimination—resulting in cumulative disadvantage over the lifespan (Smith et al. 1997; Graham et al. 2006). The recognition of groups that may experience disparities or be classified as disparate does not suggest that such communities or their individual members lack strengths and assets.

This report treats disparate and vulnerable as distinctly different terms. The term vulnerable population has been used to define the groups of people among whom tobacco-related health disparities exist and to determine focal areas of research and resources that are needed to reduce tobacco-related health disparities (Fagan et al. 2007; Lee et al. 2023). Vulnerable has been used to describe groups whose rates differ from other groups across the tobacco use continuum (initiation, current use, number of cigarettes smoked per day, addiction, quitting, access to treatment, relapse) (Fagan et al. 2007), However, vulnerable does not take into consideration cumulative disadvantage across the lifespan.^1^ For example, rates of tobacco use are higher among men than among women (USDHHS 1980, 1998, 2001). Thus, men may be seen as being vulnerable to tobacco use, but men as an aggregate sex group do not constitute a disparate group per se.

To distinguish disparate from vulnerable groups, Fagan and colleagues (2019) delineated the fundamental assumptions underlying the 2004 and 2007 definitions of tobacco-related health disparities. That is, tobacco-related health disparities are

- Not merely differences between groups along the continuum of tobacco use;
- Associated with social determinants of poorer health, such as poverty, lower education, and discrimination, which make the observed differences inequitable;
- Cumulative across the life cycle, representing a chain of events that often begins with social indicators of disadvantage; and
- Caused by social injustices (such as being uninsured) that are avoidable and can be ameliorated through policy interventions.

The definition of tobacco-related health disparities has evolved over the years and shaped a scientific discipline that influences research practices and standards and sets priorities for improving the health of all people.

#### Evolution of Terminology to Describe Groups

The terms used to describe population groups affected by health disparities have changed over time. Such terms influence the reporting of scientific data and its perception. For example, the word minority originates from the Latin word minoritas, meaning less or smaller, and was used in the early 1900s, particularly during World Wars I and II, to describe political and social groups that differed from the majority (Dalle Mulle 2019; WordSense n.d.). The term minority groups has been used to describe racial groups in the United States that were not considered part of the majority. The term minority has also been used to describe people from different sexual orientation and gender identity groups. For the past two decades, researchers have questioned how such terms as race and minority are used in scientific work and have instead defined race as a social construct because race itself lacks a scientific basis (King 1997). See “Terminology About Population Groups” earlier in this chapter for additional details about terms used in the present report, which refers to “minoritized groups.”

### Emerging Recognition of Social Determinants of Health

Underlying social, economic, and historical factors contribute to differences in health indicators along the tobacco use continuum (i.e., from initiation to health outcomes, including disease, disability, and death) and to the collective capacities and resources to ameliorate tobacco-related health disparities across the life course. Social determinants of health can perpetuate health inequities among minoritized people (CDC 2022c; Hacker et al. 2022). As noted in Healthy People 2030, social determinants of health—which are grouped into the domains of economic stability, education access and quality, healthcare access and quality, neighborhood and built environment, and social and community context—“are the conditions in the environments where people are born, live, learn, work, play, worship, and age that affect a wide range of health, functioning, and quality-of-life outcome and risks” (Office of Disease Prevention and Health Promotion n.d.b). Healthy People 2030 further states that “just promoting healthy choices won’t eliminate these and other health disparities. Instead, public health organizations and their partners in sectors like education, transportation, and housing need to take action to improve the conditions in people’s environments.”

It is well documented that people living in poverty, those with lower educational attainment, and those working in manual labor or service jobs continue to experience disproportionately higher tobacco-related health disparities (NCI 2017) (also see Chapter 2 of the current report). Furthermore, there is extensive evidence on (a) the roles of racism and discrimination in overall health and (b) the link between societal structures—including how health systems are organized—and the health of members of minoritized racial, ethnic, and other communities (Pérez-Stable and Webb Hooper 2021). Experiences of discrimination also have direct links to tobacco-related health disparities. Discrimination has historically been associated with increased tobacco use (Kendzor et al. 2014b; Chavez et al. 2015; Agunwamba et al. 2017; Crockett et al. 2018; Holmes et al. 2019), reduced cessation (Kendzor et al. 2014a; Chavez et al. 2015; Agunwamba et al. 2017; Crockett et al. 2018; Holmes et al. 2019; Webb Hooper et al. 2020) reduced access to health resources (Shavers et al. 2012), and poor treatment outcomes (Shavers et al. 2012; Simmons et al. 2016). Furthermore, in part due to the legacy of redlining,^2^ people in lower income and minoritized racial groups are more likely to live in multiunit housing, which is a physical environment that places residents at elevated risk for exposure to secondhand tobacco smoke compared with residents living in detached housing (Helms et al. 2017). In addition, studies have found that Black or African American men with similar lung cancer diagnoses and staging were not offered the same treatment regimens for lung cancer as were White men (Shavers and Brown 2002; Lathan et al. 2006).

NIH, as part of its UNITE initiative (NIH n.d.), now acknowledges that structural and systemic racism impact health disparities. Acknowledging both systemic racism (i.e., “structures, policies, practices, and norms that assign values and determine opportunities based on the way people look or the color of their skin” [CDC n.d.e]) and structural racism (i.e., racism that is “codified in our institutions of custom, practice, and law so there need not be an identifiable perpetrator” [Jones 2000, p. 1212]) is critical to addressing health disparities. Similarly, recognition of sexual orientation and gender identity diversity and of self-identification as straight; lesbian, gay, bisexual, transgender, queer, or intersex (LGBTQI+); nonbinary; or another sexual orientation or gender identity matters because (a) the tobacco industry has targeted these groups in its marketing and (b) people who identify as LGBTQI+ use tobacco at higher rates than do people who identify as heterosexual or straight.

Social disadvantage in all forms—including that predicated on race and ethnicity, income and income inequality, social and occupational status, educational attainment and opportunities, geography and place-based inequalities, sexual orientation and gender identity, and the intersections of any of these factors that groups experience—can impact tobacco-related health disparities (Dankwa-Mullan and Pérez-Stable 2016). Documenting these disparities provides the relevant data needed to inform the development of effective tobacco prevention and control programs.

### History of Tobacco Industry Marketing and Countermarketing Efforts

The tobacco industry has launched a variety of campaigns to promote tobacco products to disparate groups, including but not limited to people who are Hispanic or Latino, Native Hawaiian and Other Pacific Islander, Black or African American, and American Indian and Alaska Native; residents of rural areas; LGBTQI+ groups; and young people who identify with hip-hop culture (USDHHS 1998; Hafez and Ling 2006).

The industry’s targeting of specific populations is often informed by the industry’s in-depth psychographic research, resulting in marketing approaches that may be direct, subtle, or both (Robinson et al. 1992; Gardiner 2004; Yerger et al. 2007). Tobacco industry research and marketing has often been based on socially constructed, problematic assumptions about minoritized racial groups, including assumptions about literacy levels (Johnston 1982) and such motivations as status seeking and willingness to trust advertising (USDHHS 1998). Industry documents further show that whereas menthol brands like Kool were deliberately marketed to African American people, Marlboro cigarettes—the leading non-menthol cigarette brand—were deliberately not marketed to African American people, suggesting that marketing was not only racially and ethnically targeted but was also racially segregated by brand (Johnston 1982; Cummings et al. 1987; Landrine et al. 2005).

Marketing to the LGBTQI+ community has been similarly problematic. For example, R.J. Reynolds documents from 1995 to 1997 reveal the company’s attempts to market to the LGBTQI+ community, including through “Project Scum,” which aimed to promote Camel and Red Kamel cigarettes to “consumer subcultures” of an “alternative life style” in the San Francisco area (R.J. Reynolds 1997; Washington 2002, p. 1093). Project Scum also proposed to exploit high rates of drug use among LGBTQI+ youth by targeting head shops (i.e., shops specializing in articles of interest to drug users).

The tobacco industry outspends tobacco control efforts by a factor of at least 12 to 1 (Campaign for Tobacco-Free Kids 2023a; Federal Trade Commission 2023); the industry continues to target minoritized racial and ethnic groups, lower SES communities, and other populations (Pucci et al. 1998; Hackbarth et al. 2001; Balbach et al. 2003; Lee et al. 2004; Primack et al. 2007; Brown-Johnson et al. 2014; Trinidad et al. 2017). Chapter 5 describes contemporary examples of tobacco industry tactics that influence disparities.

### Emergence of National Tobacco Countermarketing Campaigns

State and community interventions, cessation interventions, federal regulations, and health communication interventions can effectively counter messaging from the tobacco industry (USDHHS 2014). Using revenues from state cigarette taxes and other sources, some states have launched innovative and highly successful tobacco countermarketing campaigns that have paved the way for national campaigns; the earliest such campaigns occurred in California and Massachusetts (Balbach and Glantz 1998; Tsoukalas and Glantz 2003).

The twenty-first century saw the emergence of major, national countermarketing campaigns with reach to specific groups, including,

- The Truth campaign launched by American Legacy Foundation (now Truth Initiative) in 2000 to prevent smoking among at-risk youth 12–17 years of age (Zucker et al. 2000).
- CDC’s Tips from Former Smokers launched in 2012, the first federally funded national tobacco education campaign that encourages quitting among adults. Tips advertisements have featured people who are Black or African American, American Indian and Alaska Native, Asian American, Hispanic or Latino, HIV+, LGBTQI+, military members, veterans, and pregnant women, as well as people with mental health conditions.
- FDA’s The Real Cost directed to youth, including male youth in rural areas at risk for smokeless tobacco use.
- FDA’s Fresh Empire prevention campaign targeting “at-risk multicultural youth, 12–17 years of age who identified with hip-hop culture, specifically African American, Hispanic, and Asian American/Pacific Islander youth” (FDA 2022a).
- FDA’s This Free Life directed to LGBTQI+ young adults who occasionally smoke cigarettes (FDA 2022b).

Public health mass media campaigns with relevance and reach to minoritized racial, ethnic, sexual orientation, and gender identity groups; people with lower SES; and other populations that experience tobacco-related disparities can help counter the efforts of the tobacco industry and address inequities in exposure to marketing. Continued development, testing, implementation, and evaluation of public health campaigns that reach disparate populations are critical to reducing tobacco-related health disparities (Cruz et al. 2019).

### Funding Initiatives Aimed at Reducing Tobacco-Related Health Disparities

The tobacco industry has a long history of investing in and cultivating relationships with minoritized communities. Although public health, state, and local agencies cannot compete with the vast resources of the tobacco industry, public health efforts have helped to successfully reduce the share of adult cigarette smoking by more than 70% since publication of the 1964 Surgeon General’s report (USDHHS 2014). However, this progress has not resulted in equitable outcomes for all groups.

In 1991, NCI launched the American Stop Smoking Intervention Study for Cancer Prevention (ASSIST) (NCI 2006). This $165-million investment by NCI did not specifically address tobacco-related health disparities, but it was influential at the state and local levels and later in its evolution engaged a multicultural committee that aimed to eliminate disparities among high-priority population groups. The 1998 Surgeon General’s report provided the impetus for a new focus on investing in the public health of minoritized racial and ethnic communities to blunt the effects of years of investments by the tobacco industry. Table 1.1 lists CDC-funded initiatives launched from 1997 to 2023 that are designed to address disparities. In addition to these efforts, NCI has played a key role in supporting communities in their efforts to reduce the tobacco-caused cancer burden in underserved and minoritized racial and ethnic communities and in sponsoring research on tobacco-related health disparities, including through its partnership with the American Legacy Foundation to develop the Tobacco Research Network on Disparities (TreND) (Clayton 2006; Okuyemi et al. 2015).

Nongovernmental initiatives, including those funded by the 1998 Master Settlement Agreement (MSA), have also been critical sources of funding for efforts to address disparities. The 1998 MSA between the four largest tobacco companies at the time and 46 states, 4 U.S. territories, the Commonwealth of Puerto Rico, and the District of Columbia remains the largest civil settlement in U.S. history (Public Health Law Center 2019). The MSA’s purpose was to alleviate the burden of Medicaid costs for treating tobacco-related illnesses and to develop and fund educational programs to prevent and reduce underage smoking (Public Health Law Center 2019; National Association of Attorneys General n.d.). The MSA also created the American Legacy Foundation (now Truth Initiative), which created opportunities for funding initiatives that focused on priority populations. For example, in 2001, the American Legacy Foundation launched the Priority Populations Initiative, which provided $25 million to 83 grantees with the goal of reducing tobacco-related health disparities (American Legacy Foundation n.d.).

Table 1.1 Select programmatic initiatives funded federally by CDC and designed to reduce tobacco-related health disparities, 1997–2023

Funding agency and program | Year | Purpose | Populations of focus include | No. of grants and investments
CDC National Networks | 1997 | Build capacity for smoking prevention, cessation, education, and public policy | African American people, Hispanic or Latino people, Asian American and Pacific Islander people, and American Indian and Alaska Native people, along with youth, women, males (12–24 years of age), “blue-collar” and/or agricultural workers, lower education groups, and military personnel | 8 grants; $3 million
Cooperative Agreements for National Networks for Tobacco Prevention and Control Program | 2000 | Build capacity for smoking prevention, cessation, education, and public policy | African American people, Hispanic or Latino people, Asian and Pacific Islander people, and American Indian and Alaska Native people, along with youth, women, males (12–24 years of age), “blue-collar” and/or agricultural workers, lower education groups, and military personnel | 8 awardees; up to $3 million per year for 6 years
Cooperative Agreements for National Networks for Tobacco Prevention and Control Program | 2006 | Prevent and reduce tobacco use and exposure to secondhand tobacco smoke and eliminate tobacco-related health disparities | African American people, American Indian and Alaska Native people, Asian American and Pacific Islander people, and Hispanic or Latino people | 6 awardees; $1.8 million per year for 2 years
National Network for Tobacco Prevention | 2008 | Develop a consortium of national networks to expand the science of tobacco control in populations experiencing tobacco-related health disparities. | African American people, American Indian and Alaska Native people, Asian American and Pacific Islander people, Hispanic or Latino people, and people with lower SES | 6 awardees; $12.5 million (total) over 5 years
CDC—Consortium of National Networks to Impact Populations Experiencing Tobacco-Related and Cancer Health Disparities | 2013 | Establish partnerships to provide leadership on and promotion of evidence-based approaches for preventing commercial tobacco use and cancer | African American people; American Indian and Alaska Native people, Asian American people, Pacific Islander people, Native Hawaiian people, Hispanic or Latino people, LGBT people, people with lower SES, people with mental health conditions and substance abuse disorders, and geographically defined populations with high commercial tobacco use and related disparities | Up to 10 grants; $26 million (total) over 5 years
Good Health and Wellness in Indian Country | 2015 | Promote health, prevent disease, reduce health disparities, and strengthen connections to culture and lifeways that improve health and wellness | American Indian and Alaska Native people | 35 grants; $78 million (total)
Networking2Save and CDC—National Network Approach to Preventing and Controlling Tobacco-related Cancers in Special Populations | 2018 | Implement population-specific, public health-oriented strategies that impact the prevalence of commercial tobacco use and tobacco-related cancers | African American people, American Indian and Alaskan Native people, Asian American people, Pacific Islander, and Native Hawaiian people, Hispanic or Latino people, LGBT people, people of lower SES, people with mental health conditions and substance use disorders, and geographically defined populations with high commercial tobacco use and related health disparities | 8 grants; $5.2 million (total)
Good Health and Wellness in Indian Country | 2019 | Promote health, prevent disease, reduce health disparities, and strengthen connections to culture and lifeways that improve health and wellness | American Indian and Alaska Native people | 27 grants; $19.3 million per year
Building Capacity to Reduce the Burden of Menthol and Other Flavored Commercial Tobacco Products in Communities that Experience Health Disparities | 2023 | Advance health equity through strategic partnerships and community engagement by addressing disparities caused by menthol and other flavored tobacco product marketing and use | People who use menthol cigarettes | 8 recipients; $15 million (total) over 5 years

Notes: CDC = Centers for Disease Control and Prevention; LGBT = lesbian, gay, bisexual, or transgender; SES = socioeconomic status.

However, the settlement did not require states to track their spent funds to determine how the money was being used to fund tobacco prevention and control efforts, including prevention and control efforts that focus on population groups who are disproportionately burdened by tobacco use, such as Medicaid recipients. In fiscal year 2024, states will collect an estimated $25.9 billion from the MSA and related taxes, but they are projected to spend only 2.8% of it on tobacco prevention and cessation programs—less than one-fourth of the total funding recommended by CDC (CDC 2014; Campaign for Tobacco-Free Kids 2024). Furthermore, differences in total amount spent as a function of CDC-recommended funding are noted by state, with only one state (Maine) funding tobacco prevention and cessation programs at or above the level recommended by CDC (Campaign for Tobacco-Free Kids 2024). In contrast, 19 states fund tobacco control efforts at less than 10% of the CDC-recommended level, many of which also have a higher burden of tobacco use (CDC 2021; Campaign for Tobacco-Free Kids 2024). It is not known how much of the settlement funds are spent on Medicaid or to alleviate tobacco-related Medicaid costs, and many states have used their MSA funds to subsidize budgetary shortfalls and for other general purposes unrelated to addressing tobacco-related health disparities specifically, or tobacco prevention and control generally (Jones and Silvestri 2010).

In addition to the aforementioned programmatic initiatives, quitlines are an evidence-based intervention that help people quit smoking by offering counseling; practical information on how to quit; referrals to other cessation resources; self-help materials; and, in some cases, cessation pharmacotherapy (USDHHS 2020). In 1992, California became the first state to launch a quitline, and other states—such as Arizona, Massachusetts, and Oregon—followed by the mid-1990s. (North American Quitline Consortium n.d.). In 2004, a single national quitline portal number (1-800-QUIT-NOW)—funded through a partnership between NCI and CDC—was launched to connect callers across the country to quitline services (USDHHS 2020; National Center for Chronic Disease Prevention and Health Promotion n.d.). Quitlines are currently available in all 50 states, Washington, D.C., and all U.S. territories. Quitlines have developed culturally tailored services to meet the needs of members of under-served groups, such as American Indian, Hispanic or Latino, and Asian American people, and provide services in multiple languages, including Spanish and languages spoken by Asian American people. In addition to quitlines, federal programs—such as federally funded health centers, which serve lower income patients, the uninsured, and Medicaid beneficiaries, among other patients—screen for tobacco use and offer cessation counseling.

Notwithstanding these important efforts, the allocation of limited public health resources involves prioritization, which often has not favored investment of time and resources to help understand and address disparities. The 1998 Surgeon General’s report identified specific tobacco control and educational programs that targeted four racial and ethnic communities, but it acknowledged significant shortcomings in investments made by public health agencies and others for prevention and cessation initiatives in those communities (USDHHS 1998). These longstanding shortcomings in investments in research and programmatic efforts contribute to tobacco-related health disparities.

### History of Advocacy to Address Menthol and Other Flavored Tobacco Products

Menthol cigarettes mask the harshness of cigarette smoke (The Roper Organization 1979; Creative Research Group Limited 1982; Yerger 2011; Center for Tobacco Products 2022), facilitate addiction (Ahijevych and Garrett 2010; Fagan et al. 2010; Hoffman and Simmons 2011; Yerger 2011; Center for Tobacco Products 2022), make quitting more difficult (Yerger 2011; Center for Tobacco Products 2022), and are disproportionately used by certain racial and ethnic groups, LGBTQI+ people, women, and young people (see Chapter 2). The Family Smoking Prevention and Tobacco Control Act (Tobacco Control Act [2009]) gave FDA the authority to regulate the manufacture, distribution, and marketing of tobacco products in the United States. The Act banned cigarettes with characterizing flavors, except those with menthol or tobacco flavors (FDA 2018, p. 3), and directed the Tobacco Products Scientific Advisory Committee (TPSAC) to study the impact of menthol on public health and make a recommendation to FDA. In a 2011 report, TPSAC concluded that “removal of menthol cigarettes from the marketplace would benefit public health in the United States” (TPSAC 2011, p. 225).

Prior to passage of the Tobacco Control Act, some tobacco control advocates—such as the National African American Tobacco Prevention Network—opposed menthol’s exclusion from the legislation (Cheyne et al. 2014). After the Act’s enactment, advocacy efforts continued to encourage a federal ban on menthol-flavored cigarettes. In 2013, advocates filed a formal petition, the “Citizen Petition Asking the Food and Drug Administration to Prohibit Menthol as a Characterizing Flavor in Cigarettes” and citing the TPSAC’s 2011 conclusions (Tobacco Control Legal Consortium n.d.). In 2020, the African American Tobacco Control Leadership Council (2020) and Action on Smoking & Health (2020) filed a lawsuit seeking to compel FDA to respond to the 2013 citizen petition and to issue a product standard to prohibit menthol as a characterizing flavor in cigarettes (Public Health Law Center et al. 2013). In May 2022, FDA proposed such a product standard, to cover both cigarettes and cigarette components or parts, including those sold separately to consumers (Federal Register 2022a), and proposed a product standard to prohibit characterizing flavors, except tobacco flavor, in cigars (Federal Register 2022b).

While these important developments unfolded at the federal level, states and localities have helped to build momentum to protect their residents from flavored tobacco products. The Tobacco Control Act (2009) affirms state, territorial, tribal, and local authority to adopt and enforce requirements related to the sale, distribution, exposure to, access to, advertising and promotion of, or use of tobacco products by individuals of any age, among other actions.^3^ As of 2023, two states (Massachusetts and California) and nearly 200 U.S. communities prohibit the sale of menthol cigarettes and other flavored tobacco products, protecting about one-sixth of the population (Campaign for Tobacco-Free Kids 2023b; Truth Initiative 2023). Prohibiting the sale of flavored tobacco products in Massachusetts was associated with a statistically significant decrease in the sale of menthol cigarettes and all cigarettes (Asare et al. 2022). Local laws restricting the sale of flavored tobacco products are associated with a decrease in tobacco product sales and in the prevalence of tobacco use among youth (Rogers et al. 2022). Chapters 6 and 7 discuss more fully these and other studies that estimate the potential impact of a federal standard on menthol products. In addition to policies that prohibit the sale of menthol and other flavored tobacco products, the evaluation of these policies may help to foster a better understanding of their impact on reducing tobacco-related health disparities in the United States.

## Conclusions

1. The complex and centuries-long historical context of tobacco commercialization is a foundational driver of present-day tobacco-related health disparities.
2. For decades, tobacco-related health disparities have not received the necessary investments of research, time, and resources.
3. Poverty, racism, and discrimination are important and long-standing social and structural determinants that marginalize minoritized racial, ethnic, gender identity, and sexual orientation groups and provide the context in which tobacco-related health disparities have occurred for many decades.
4. Not all vulnerable groups are disparate groups. A disparate group is not only vulnerable to tobacco use but may also face social determinants of poor health (e.g., poverty), cumulative indicators of social disadvantage across the lifespan, and historic injustices.
5. Tobacco industry marketing has historically targeted minoritized racial and ethnic groups and sexual orientation and gender identity groups.
6. States and localities have helped to build momentum to enact and implement policies that prohibit the sale of menthol cigarettes and other flavored tobacco products.

## References

African American Tobacco Control Leadership Council et al. v. U.S. Department of Health and Human Services et al., No. 4:20-cv-04012 (N.D. Cal. complaint filed June 17, 2020).
Agunwamba AA, Kawachi I, Williams DR, Finney Rutten LJ, Wilson PM, Viswanath K. Mental health, racial discrimination, and tobacco use differences across rural-urban California. Journal of Rural Health 2017;33(2):180–9.
Ahijevych K, Garrett BE. The role of menthol in cigarettes as a reinforcer of smoking behavior. Nicotine & Tobacco Research 2010;(12 Suppl 2):S110–S116.
American Legacy Foundation. Priority Populations Initiative: Breaking New Ground and Building Capacity in Cultural Tailoring. Washington (DC): American Legacy Foundation, n.d.
American Indian Religious Freedom Act of 1978, Public Law 95–341, U.S. Statutes at Large 92 (1978):469, codified at U.S. Code 42 (1978):1996.
American Indian Religious Freedom Act Amendments of 1994, Public Law 103–344, U.S. Statutes at Large 108 (1994):3125.
Asare S, Majmundar A, Westmaas JL, Bandi P, Xue Z, Jemal A, Nargis N. Association of cigarette sales with comprehensive menthol flavor ban in Massachusetts. JAMA Internal Medicine 2022;182(2):231–4.34982100
Balbach ED, Gasior RJ, Barbeau EM. R.J. Reynolds’ targeting of African Americans: 1988–2000. American Journal of Public Health 2003;93(5):822–7.12721151
Balbach ED, Glantz SA. Tobacco control advocates must demand high-quality media campaigns: the California experience. Tobacco Control 1998;7(4):397–408.10093175
Brown-Johnson CG, England LJ, Glantz SA, Ling PM. Tobacco industry marketing to low socioeconomic status women in the U.S.A. Tobacco Control 2014; 23(e2):e139–e146.24449249
Campaign for Tobacco-Free Kids. State Tobacco Prevention Spending vs. Tobacco Company Marketing, December 22, 2023a; <https://www.tobaccofreekids.org/assets/content/what_we_do/state_local_issues/settlement/FY2023/5-State-Tobacco-Prevention-Spending-vs-Tobacco-Company-Marketing.pdf>; accessed: February 22, 2024.
Campaign for Tobacco-Free Kids. States & Localities That Have Restricted the Sale of Flavored Tobacco Products, 2023b; <https://www.tobaccofreekids.org/assets/factsheets/0398.pdf>; accessed: July 27, 2023.
Campaign for Tobacco-Free Kids. Broken Promises to Our Children: A State-by-State Look at the 1998 Tobacco Settlement 25 Years Later, January 2024; <https://www.tobaccofreekids.org/what-we-do/us/statereport/>; accessed: February 28, 2024.
Center for Tobacco Products. Scientific Review of the Effects of Menthol in Cigarettes on Tobacco Addiction: 1980–2021, 2022; <https://www.fda.gov/media/157642/download>; accessed: May 17, 2022.
Centers for Disease Control and Prevention. Best Practices for Comprehensive Tobacco Control Programs—2014. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2014; <https://www.cdc.gov/tobacco/stateandcommunity/guides/pdfs/2014/comprehensive.pdf>; accessed: July 26, 2017.
Centers for Disease Control and Prevention. Best Practices User Guide: Health Equity in Tobacco Prevention and Control. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2015.
Centers for Disease Control and Prevention. Map of current cigarette use among adults, October 22, 2021; <https://www.cdc.gov/statesystem/cigaretteuseadult.html>; accessed: February 23, 2024.
Centers for Disease Control and Prevention. Inclusive communication principles: key principles, 2022a; <https://www.cdc.gov/healthcommunication/Key_Principles.html>; accessed: November 15, 2022.
Centers for Disease Control and Prevention. Unfair and unjust practices and conditions harm Asian, Native Hawaiian, and Pacific Islander people and drive health disparities, 2022b; <https://www.cdc.gov/tobacco/health-equity/anhpi/unfair-and-unjust.html>; accessed: September 15, 2022.
Centers for Disease Control and Prevention. Why is addressing social determinants of health important for CDC and public health?, December 8, 2022c; <https://www.cdc.gov/about/sdoh/addressing-sdoh.html>; accessed: August 22, 2023.
Centers for Disease Control and Prevention. Racism and health: racism is a serious threat to the public’s health, n.d.; <https://www.cdc.gov/minorityhealth/racism-disparities/index.html>; accessed: November 14, 2022.
Chavez LJ, Ornelas IJ, Lyles CR, Williams EC. Racial/ethnic workplace discrimination: association with tobacco and alcohol use. American Journal of Preventive Medicine 2015;48(1):42–9.25441232
Cheyne A, Dorfman L, Daynard RA, Mejia P, Gottlieb M. The debate on regulating menthol cigarettes: closing a dangerous loophole vs freedom of choice. American Journal of Public Health 2014;104(7):e54–e61.
Clayton RR. The Tobacco Research Network on Disparities (TReND). Journal of Epidemiology and Community Health 2006;60(Suppl 2):3–4.
Cole ER. Intersectionality and research in psychology. American Psychologist 2009;64(3):170–80.19348518
Cooper R, David R. The biological concept of race and its application to public health and epidemiology. Journal of Health Politics, Policy and Law 1986;11(1):97–116.3722786
Creative Research Group Limited. Project Crawford: Phase 1:7 Group Discussions. June 1982. British American Tobacco Records Collection. Bates No. 102686774-102686822. <https://www.industrydocuments.ucsf.edu/tobacco/docs/#id=ktll0200>.
Crockett KB, Rice WS, Turan B. Associations between multiple forms of discrimination and tobacco use among people living with HIV: the mediating role of avoidance coping. Journal of Acquired Immune Deficiency Syndromes 2018;78(1):9–15.29373394
Cruz TB, Rose SW, Lienemann BA, Byron MJ, Meissner HI, Baezconde-Garbanati L, Huang LL, Carroll DM, Soto C, Unger JB. Pro-tobacco marketing and anti-tobacco campaigns aimed at vulnerable populations: a review of the literature. Tobacco Induced Diseases 2019;17:68.31582956
Cummings KM, Giovino G, Mendicino AJ. Cigarette advertising and black-white differences in brand preference. Public Health Reports 1987;102(6):698–701.3120235
Dalle Mulle E. Some thoughts on the origins of the postWWI minorities regime, November 20, 2019; <https://networks.h-net.org/node/3911/discussions/5403423/some-thoughts-origins-post-wwi-minorities-regime>; accessed: November 14, 2022.
Dankwa-Mullan I, Pérez-Stable EJ. Addressing health disparities is a place-based issue. American Journal of Public Health 2016;106(4):637–9.26959267
Encyclopedia Virginia. Convicts sent to Virginia, Virginia Gazette, 1737; <https://encyclopediavirginia.org/3853hpr-c2bd8c02673e24c/>; accessed: April 7, 2023.
Fagan P, Guy M, Alexander L, Oliver V. The casualties left behind in tobacco’s cinders of combustion. Current Addiction Reports 2019;6:183–90.33312838
Fagan P, King G, Lawrence D, Petrucci SA, Robinson RG, Banks D, Marable S, Grana R. Eliminating tobacco-related health disparities: directions for future research. American Journal of Public Health 2004;94(2):211–7.14759929
Fagan P, Moolchan ET, Hart A Jr, Rose A, Lawrence D, Shavers VL, Gibson JT. Nicotine dependence and quitting behaviors among menthol and non-menthol smokers with similar consumptive patterns. Addiction 2010; 105(Suppl 1):55–74.21059137
Fagan P, Moolchan ET, Lawrence D, Fernander A, Ponder PK. Identifying health disparities across the tobacco continuum. Addiction 2007;102(Suppl 2):5–29.
Family Smoking Prevention and Tobacco Control Act, Public Law 111–31, 123 U.S. Statutes at Large 1776 (2009).
Federal Register. Executive Office of the President, Office of Management and Budget, Office of Information and Regulatory Affairs. Revisions to the standards for the classification of federal data on race and ethnicity, 62 Fed. Reg. 210 (1997).
Federal Register. U.S. Department of Health and Human Services, Food and Drug Administration. Tobacco product standard for menthol in cigarettes, proposed rule (21 CFR 1162), 87 Fed. Reg. 26454 (2022a).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Tobacco product standard for characterizing flavors in cigars; proposed rule (21 CFR Part 1166), 87 Fed. Reg. 26396 (2022b).
Federal Trade Commission. FTC releases reports on cigarette and smokeless tobacco sales and marketing expenditures for 2022: sales of nicotine lozenges, pucks, and pouches more than doubled in two years, October 30, 2023; <https://www.ftc.gov/news-events/news/press-releases/2023/10/ftc-releases-reports-cigarette-smokeless-tobacco-sales-marketing-expenditures-2022>; accessed: February 22, 2024.
Flanagin A, Frey T, Christiansen SL, AMA Manual of Style Committee. Updated guidance on the reporting of race and ethnicity in medical and science journals. JAMA: the Journal of the American Medical Association 2021;326(7):621–7.34402850
Ford CL, Harawa NT. A new conceptualization of ethnicity for social epidemiologic and health equity research. Social Science & Medicine 2010;71(2):251–8.20488602
Gardiner PS. The African Americanization of menthol cigarette use in the United States. Nicotine & Tobacco Research 2004;6(Suppl 1):S55–S65.14982709
Graham H, Inskip HM, Francis B, Harman J. Pathways of disadvantage and smoking careers: evidence and policy implications. Journal of Epidemiology and Community Health 2006;60(Suppl 2):7–12.
Hackbarth DP, Schnopp-Wyatt D, Katz D, Williams J, Silvestri B, Pfleger M. Collaborative research and action to control the geographic placement of outdoor advertising of alcohol and tobacco products in Chicago. Public Health Reports 2001;116(6):558–67.12196615
Hacker K, Auerbach J, Ikeda R, Philip C, Houry D. Social determinants of health—an approach taken at CDC. Journal of Public Health Management and Practice 2022;28(6):589–94.36194813
Hafez N, Ling PM. Finding the Kool Mixx: how Brown & Williamson used music marketing to sell cigarettes. Tobacco Control 2006;15(5):359–66.16998169
Haiman CA, Stram DO, Wilkens LR, Pike MC, Kolonel LN, Henderson BE, Le Marchand L. Ethnic and racial differences in the smoking-related risk of lung cancer. New England Journal of Medicine 2006;354(4):333–42.16436765
Helms VE, King BA, Ashley PJ. Cigarette smoking and adverse health outcomes among adults receiving federal housing assistance. Preventive Medicine 2017; 99:171–7.28192095
Hodge FW. Handbook of American Indians North of Mexico. Bulletin No. 30. Washington (DC): Smithsonian Institution, Bureau of American Ethnology, 1910.
Hoffman AC, Simmons D. Menthol cigarette smoking and nicotine dependence. Tobacco Induced Diseases 2011;9(Suppl 1):S5.21624151
Holmes LM, Lea Watkins S, Lisha NE, Ling PM. Does experienced discrimination explain patterns of menthol use among young adults? Evidence from the 2014 San Francisco Bay Area Young Adult Health Survey. Substance Use & Misuse 2019;54(7):1106–14.30747029
Hood CM, Gennuso KP, Swain GR, Catlin BB. County health rankings: relationships between determinant factors and health outcomes. American Journal of Preventive Medicine 2016;50(2):129–35. House Concurrent Resolution 108, U.S. Statutes at Large 67 (1953):B132.26526164
Institute of Medicine. Unequal Treatment: Confronting Racial and Ethnic Disparities in Health Care. Washington (DC): The National Academies Press, 2003.
Johnston M. Newport Smokers. November 18, 1982. Philip Morris Records Collection. Bates No. 39904970843990497097. <https://www.industrydocuments.ucsf.edu/docs/fqnn0189>.
Jones BW. Race, sex, and class: black female tobacco workers in Durham, North Carolina, 1920–1940, and the development of female consciousness. Feminist Studies 1984;10(3):441–51.
Jones CP. Levels of racism: a theoretic framework and a gardener’s tale. American Journal of Public Health 2000;90(8):1212–5.10936998
Jones WJ, Silvestri GA. The Master Settlement Agreement and its impact on tobacco use 10 years later: lessons for physicians about health policy making. Chest 2010;137(3):692–700.20202950
Keep It Sacred. Traditional tobacco, n.d.; <https://keepitsacred.itcmi.org/tobacco-and-tradition/traditional-tobacco-use/>; accessed: March 2, 2022.
Kendzor DE, Businelle MS, Reitzel LR, Castro Y, Vidrine JI, Mazas CA, Cinciripini PM, Lam CY, Adams CE, Correa-Fernández V, et al. The influence of discrimination on smoking cessation among Latinos. Drug and Alcohol Dependence 2014a;136:143–8.24485880
Kendzor DE, Businelle MS, Reitzel LR, Rios DM, Scheuermann TS, Pulvers K, Ahluwalia JS. Everyday discrimination is associated with nicotine dependence among African American, Latino, and White smokers. Nicotine & Tobacco Research 2014b;16(6):633–40.24302634
Kickbusch I, Allen L, Franz C. The commercial determinants of health. Lancet Global Health 2016;4(12): e895–e896.27855860
King BA, Creamer MR, Harrell M, Kelder S, Norman L, Perry CL. Surgeon General’s reports on tobacco: a continued legacy of unbiased and rigorous synthesis of the scientific evidence. Nicotine & Tobacco Research 2018; 20(8):1033–6.29300946
King G. The “race” concept in smoking: a review of the research on African Americans. Social Science & Medicine 1997;45(7):1075–87.9257399
King G, editor. Eliminating Tobacco-Related Health Disparities: Summary Report—National Conference on Tobacco and Health Disparities: Forging a National Research Agenda to Reduce Tobacco-Related Health Disparities. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2005.
Kulikoff A. Tobacco and Slaves: The Development of Southern Cultures in the Chesapeake, 1680–1800. Chapel Hill (NC): University of North Carolina Press, 1986.
Landrine H, Klonoff EA, Fernandez S, Hickman N, Kashima K, Parekh B, Thomas K, Brouillard CR, Zolezzi M, Jensen JA, . Cigarette advertising in Black, Latino, and White magazines, 1998–2002: an exploratory investigation. Ethnicity & Disease 2005;15(1):63–7.15720050
Lathan CS, Neville BA, Earle CC. The effect of race on invasive staging and surgery in non-small-cell lung cancer. Journal of Clinical Oncology 2006;24(3):413–8.16365180
Lee D, Cutler BD, Burns J. The marketing and demarketing of tobacco products to low-income African-Americans. Health Marketing Quarterly 2004;22(2):51–68.15914374
Lee JP, Maddox R, Kennedy M, Nahvi S, Guy MC. Off-White: decentring Whiteness in tobacco science. Tobacco Control 2023;32(5):537–9.37591558
Legal Information Institute. Redlining, n.d.; <https://www.law.cornell.edu/wex/redlining>; accessed: December 21, 2022.
Marshall M. Drinking Smoke: The Tobacco Syndemic in Oceania. Honolulu (HI): University of Hawai’i Press, 2013.
McLeroy KR, Bibeau D, Steckler A, Glanz K. An ecological perspective on health promotion programs. Health Education Quarterly 1988;15(4):351–77.3068205
Mendez DD, Spriggs AL. Race as a social construct: the genetic fallacy. American Journal of Obstetrics and Gynecology 2008;198(4):484.18395050
Merriam-Webster. Racialize, n.d.; <http://www.merriam-webster.com/dictionary/racialize>; accessed: June 7, 2022.
Mialon M. An overview of the commercial determinants of health. Globalization and Health 2020;16(1):74.32807183
Mitchell T, Arseneau C, Thomas D. Colonial trauma: complex, continuous, collective, cumulative and compounding effects on the health of Indigenous peoples in Canada and beyond. International Journal of Indigenous Health 2019;14(2):74–94.
Munford LA, Panagioti M, Bower P, Skevington SM. Community asset participation and social medicine increases qualities of life. Social Science & Medicine 2020;259:113149.32603958
National Archives. Milestone documents: Dawes Act (1887), n.d.; <https://www.archives.gov/milestone-documents/dawes-act>; accessed: November 14, 2022.
National Association of Attorneys General. The Master Settlement Agreement, n.d.; <https://www.naag.org/our-work/naag-center-for-tobacco-and-public-health/the-master-settlement-agreement/>; accessed: January 25, 2023.
National Cancer Institute. Evaluating ASSIST: A Blueprint for Understanding State-level Tobacco Control. Tobacco Control Monograph No. 17. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2006.
National Cancer Institute. A Socioecological Approach to Addressing Tobacco-Related Health Disparities. Tobacco Control Monograph 22. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2017. NIH Publication No. 17-CA-8035A.
National Center for Chronic Disease Prevention and Health Promotion. Frequently Asked Questions (FAQ) About 1-800-QUIT-NOW and the National Network of Tobacco Cessation Quitlines, n.d.; <https://www.cdc.gov/tobacco/quit_smoking/cessation/pdfs/faq-1800-quit-now-factsheet-p.pdf>; accessed: August 22, 2023.
National Center for Health Statistics. Healthy People 2010 Final Review. Hyattsville (MD): National Center for Health Statistics, 2012.
National Geographic. Native Americans and freedom of religion, n.d.; accessed: June 17, 2022.
National Institutes of Health. NIH Style Guide: Race and national origin, 2024; <https://www.nih.gov/nih-style-guide/race-national-origin>; accessed: February 22, 2024.
National Institutes of Health. UNITE n.d.; <https://www.nih.gov/ending-structural-racism/unite>; accessed: June 24, 2022.
Native Voices. 1953: Congress seeks to abolish tribes, relocate American Indians, 1953; <https://www.nlm.nih.gov/nativevoices/timeline/488.html>; accessed: August 3, 2022.
Nez Henderson P, Lee JP, Soto C, O’Leary R, Rutan E, D’Silva J, Waa A, Henderson ZP, Nez SS, Maddox R. Decolonization of tobacco in indigenous communities of Turtle Island (North America). Nicotine & Tobacco Research 2022;24(2):289–91.34516637
North American Quitline Consortium. History, n.d.; <https://www.naquitline.org/page/History>; accessed: December 23, 2020.
Office of Disease Prevention and Health Promotion. Social determinants, n.d.a; <https://wayback.archive-it.org/5774/20220413204846/https://www.healthypeople.gov/2020/leading-health-indicators/2020-lhi-topics/Social-Determinants>; accessed: April 30, 2020.
Office of Disease Prevention and Health Promotion. Social determinants of health, n.d.b; <https://health.gov/healthypeople/priority-areas/social-determinants-health>; accessed: June 24, 2022.
Office of the Chief Statistician of the United States. Recommendations on the Best Practices for the Collection of Sexual Orientation and Gender Identity Data on Federal Statistical Surveys, 2023; <https://www.whitehouse.gov/wp-content/uploads/2023/01/SOGI-Best-Practices.pdf>; accessed: February 22, 2024.
Okuyemi KS, Reitzel LR, Fagan P. Interventions to reduce tobacco-related health disparities. Nicotine & Tobacco Research 2015;17(8):887–91.26180213
Pérez-Stable EJ, Webb Hooper M. Acknowledgment of the legacy of racism and discrimination. Ethnicity & Disease 2021;31(Suppl 1):289–92.34045830
Powers M, Faden R. Structural Injustice: Power, Advantage, and Human Rights. New York (NY): Oxford University Press, 2019.
Primack BA, Bost JE, Land SR, Fine MJ. Volume of tobacco advertising in African American markets: systematic review and meta-analysis. Public Health Reports 2007; 122(5):607–15.17877308
Public Health Law Center. The Master Settlement Agreement: An Overview, 2019; <https://www.publichealthlawcenter.org/sites/default/files/resources/MSA-Overview-2019.pdf>; accessed: March 9, 2020.
Public Health Law Center . Citizen Petition Asking the U.S. Food and Drug Administration to Prohibit Menthol as a Characterizing Flavor in Cigarettes, April 12, 2013; <https://www.publichealthlawcenter.org/sites/default/files/resources/tclc-fdacitizenpetition-menthol-2013.pdf>; accessed: October 5, 2021.
Pucci LG, Joseph HM Jr, Siegel M. Outdoor tobacco advertising in six Boston neighborhoods. Evaluating youth exposure. American Journal of Preventive Medicine 1998;15(2):155–9.9713672
R.J. Reynolds. Project SCUM. 1997. R.J. Reynolds Records Collection. Bates No. 517060265-517060272. <https://www.industrydocuments.ucsf.edu/docs/grjx0094>.
Robinson RG, Barry M, Bloch M, Glantz S, Jordan J, Murray KB, Popper E, Sutton C, Tarr-Whelan K, Themba M, . Report of the Tobacco Policy Research Group on marketing and promotions targeted at African Americans, Latinos, and women. Tobacco Control 1992;1(Suppl 1):S24–S30.
Rogers T, Brown EM, Siegel-Reamer L, Rahman B, Feld AL, Patel M, Vallone D, Schillo BA. A comprehensive qualitative review of studies evaluating the impact of local U.S. laws restricting the sale of flavored and menthol tobacco products. Nicotine & Tobacco Research 2022;24(4):433–43.34525207
Shavers VL, Brown ML. Racial and ethnic disparities in the receipt of cancer treatment. Journal of the National Cancer Institute 2002;94(5):334–57.11880473
Shavers VL, Fagan P, Jones D, Klein WM, Boyington J, Moten C, Rorie E. The state of research on racial/ethnic discrimination in the receipt of health care. American Journal of Public Health 2012;102(5):953–66.22494002
Sherman G. Tobacco pipes of the Western Eskimos. Beaver 1972;303(1):49–51.
Simmons VN, Pineiro B, Hooper MW, Gray JE, Brandon TH. Tobacco-related health disparities across the cancer care continuum. Cancer Control 2016;23(4):434–41.27842333
Smith GD, Hart C, Blane D, Gillis C, Hawthorne V. Lifetime socioeconomic position and mortality: prospective observational study. BMJ 1997;314(7080):547–52.9055712
Sotto-Santiago S. Time to reconsider the word minority in academic medicine. Journal of Best Practices in Health Professions Diversity 2019;12(1):72–8.
Stepanikova I, Oates GR. Perceived discrimination and privilege in health care: the role of socioeconomic status and race. American Journal of Preventive Medicine 2017;52(1S1):S86–S94.27989297
Stram DO, Park SL, Haiman CA, Murphy SE, Patel Y, Hecht SS, Le Marchand L. Racial/ethnic differences in lung cancer incidence in the Multiethnic Cohort Study: an update. Journal of the National Cancer Institute 2019;111(8):811–9.30698722
Swope CB, Hernandez D, Cushing LJ. The relationship of historical redlining with present-day neighborhood environmental and health outcomes: a scoping review and conceptual model. Journal of Urban Health 2022;99(6):959–83.35915192
The Lancet Healthy Longevity. Compounding inequalities: racism, ageism, and health [editorial]. The Lancet Healthy Longevity 2021;2(3):e112.36098107
The Roper Organization. Study of Smoker’s Habits and Attitudes with Special Emphasis on Low Tar and Menthol Cigarettes, Volume I. March 1979. Philip Morris Records Collection. Bates No. 2049455309-2049455318. <https://www.industrydocuments.ucsf.edu/docs/#id=rjmd0125>.
Tobacco Control Legal Consortium. Public Health Leaders Petition the FDA to Act on Menthol: Citizen Petition Highlights, n.d.; <https://tobaccopolicycenter.org/wp-content/uploads/2017/11/576.pdf>; accessed: February 19, 2019.
Tobacco Products Scientific Advisory Committee. Menthol Cigarettes and Public Health: Review of the Scientific Evidence and Recommendations. Washington (DC): U.S. Food and Drug Administration, 2011.
Trinidad DR, Blanco L, Emery SL, Fagan P, White MM, Reed MB. Associations between cigarette print advertising and smoking initiation among African Americans. Journal of Racial and Ethnic Health Disparities 2017; 4(3):515–22.27337978
Truth Initiative. Flavored tobacco policy restrictions as of September 30, 2023, 2023; <https://truthinitiative.org/sites/default/files/media/files/2024/01/Flavored-tobacco-policy-restrictions-Sept.30.2023.pdf>; accessed: February 22, 2024.
Tsoukalas TH, Glantz SA. Development and destruction of the first state funded anti-smoking campaign in the U.S.A. Tobacco Control 2003;12(2):214–20.12773734
U.S. Department of Health, Education, and Welfare. Smoking and Health: Report of the Advisory Committee to the Surgeon General of the Public Health Service. Washington (DC): U.S. Department of Health, Education, and Welfare, Public Health Service, Center for Disease Control, 1964. PHS Publication No. 1103.
U.S. Department of Health and Human Services. The Health Consequences of Smoking for Women. A Report of the Surgeon General. Washington: U.S. Department of Health and Human Services, Public Health Service, Office of the Assistant Secretary for Health, Office on Smoking and Health, 1980.
U.S. Department of Health and Human Services. Tobacco Use Among U.S. Racial/Ethnic Minority Groups—African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1998.
U.S. Department of Health and Human Services. Healthy People 2010: Understanding and Improving Health. Washington (DC): U.S. Government Printing Office; 2000a.
U.S. Department of Health and Human Services. Reducing Tobacco Use. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2000b.
U.S. Department of Health and Human Services. Women and Smoking. A Report of the Surgeon General. Rockville (MD): U.S. Department of Health and Human Services, Public Health Service, Office of the Surgeon General, 2001.
U.S. Department of Health and Human Services. The Health Consequences of Smoking: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2004.
U.S. Department of Health and Human Services. The Health Consequences of Involuntary Exposure to Tobacco Smoke: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, Coordinating Center for Health Promotion, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2006.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2012.
U.S. Department of Health and Human Services. The Health Consequences of Smoking—50 Years of Progress: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2014.
U.S. Department of Health and Human Services. Smoking Cessation. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2020.
U.S. Department of Justice. Justice Department announces new initiative to combat redlining [press release], October 22, 2021; <https://www.justice.gov/opa/pr/justice-department-announces-new-initiative-combat-redlining>; accessed: December 21, 2022.
U.S. Food and Drug Administration. Fresh Empire campaign, 2022a; <https://www.fda.gov/tobacco-products/public-health-education-campaigns/fresh-empire-campaign>; March 6, 2024.
U.S. Food and Drug Administration. Section 907 of the Federal Food, Drug, and Cosmetic Act—tobacco product standards, January 7, 2018; <https://www.fda.gov/tobacco-products/rules-regulations-and-guidance/section-907-federal-food-drug-and-cosmetic-act-tobacco-product-standards>; accessed: February 24, 2020.
U.S. Food and Drug Administration. This Free Life campaign, March 11, 2022b; <https://www.fda.gov/TobaccoProducts/PublicHealthEducation/PublicEducationCampaigns/ThisFreeLifeCampaign/default.htm>; accessed: August 22, 2023.
Unger JB, Soto C, Baezconde-Garbanati L. Perceptions of ceremonial and nonceremonial uses of tobacco by American-Indian adolescents in California. Journal of Adolescent Health 2006;38(4):443.e9–443.e16.
Wallerstein N, Muhammad M, Sanchez-Youngman S, Rodriguez Espinosa P, Avila M, Baker EA, Barnett S, Belone L, Golub M, Lucero J, . Power dynamics in community-based participatory research: a multiple-case study analysis of partnering contexts, histories, and practices. Health Education & Behavior 2019; 46(1 Suppl):19S–32S.31549557
Washington HA. Burning love: big tobacco takes aim at LGBT youths. American Journal of Public Health 2002;92(7):1086–95.12084686
Webb Hooper M, Calixte-Civil P, Verzijl C, Brandon KO, Asfar T, Koru-Sengul T, Antoni MH, Lee DJ, Simmons VN, Brandon TH. Associations between perceived racial discrimination and tobacco cessation among diverse treatment seekers. Ethnicity & Disease 2020;30(3):411–20.32742143
Whitehead M, Dahlgren G. Levelling Up (Part 1): A Discussion Paper on Concepts and Principles for Tackling Social Inequities in Health. Copenhagen (Denmark): World Health Organization, Regional Office for Europe, 2006.
Witherspoon DP, Bamaca-Colbert MY, Stein GL, Rivas-Drake D. Hidden populations: uncovering the developmental experiences of minoritized populations across contexts. Developmental Psychology 2020;56(8):1425–30.32790442
Witzig R. The medicalization of race: scientific legitimization of a flawed social construct. Annals of Internal Medicine 1996;125(8):675–9.8849153
WordSense. Minoritatem, n.d.; <https://www.wordsense.eu/minoritatem/>; accessed: November 14, 2022.
Yerger VB. Menthol’s potential effects on nicotine dependence: a tobacco industry perspective. Tobacco Control 2011;20(Suppl 2):ii29–ii36.21504929
Yerger VB, Przewoznik J, Malone RE. Racialized geography, corporate activity, and health disparities: tobacco industry targeting of inner cities. Journal of Health Care for the Poor and Underserved 2007;18(4 Suppl):10–38.18065850
Zucker D, Hopkins RS, Sly DF, Urich J, Kershaw JM, Solari S. Florida’s “truth” campaign: a counter-marketing, anti-tobacco media campaign. Journal of Public Health Management and Practice 2000;6(3):1–6. Suppl):10–38.

## Chapter 1 Appendices

### Appendix 1.1 Terminology Used in this Surgeon General’s Report

#### Acculturation

The process in which a non-majority culture is exposed to a dominant culture and adapts to the cultural beliefs and practices of the dominant culture (Rothe et al. 2010).

#### Age-specific population groups

- Youth (12–17 years of age)
- Young adults (18–25 years of age)
- All adults (18 years of age and older) (Substance Abuse and Mental Health Services Administration 2020).

#### Commercial versus traditional or sacred tobacco

Commercial tobacco is manufactured tobacco sold by tobacco companies for personal use. Commercial tobacco use is the most prevalent form of tobacco use in the United States and is responsible for impacts on the health of historically disadvantaged groups, including among American Indian and Alaska Native populations (NCI 2017). Traditional or sacred tobacco is tobacco and/or other plant mixtures grown or harvested and used by some American Indian communities for ceremonial or religious purposes (Unger et al. 2006; Keep It Sacred n.d.).

#### Endgame approaches in tobacco control

Efforts to eliminate the burden of death and disease caused by commercial tobacco use (USDHHS 2014).

#### Equality versus equity

“Equality means each individual or group of people is given the same resources or opportunities. Equity recognizes that each person has different circumstances and allocates the exact resources and opportunities needed to reach an equal outcome” (The George Washington University, Milken Institute School of Public Health 2020).

#### Gender identity

A person’s deeply felt, internal, and individual experience of gender, which may or may not correspond to the person’s physiology or designated sex at birth (World Health Organization n.d.).

#### Health equity

The state in which everyone has a fair and just opportunity to attain their highest level of health and no one is “disadvantaged from achieving this potential because of their social position or other socially determined circumstance” (Brennan Ramirez et al. 2008, p. 6, citing Whitehead and Dahlgreen 2006; CDC n.d.). Achieving this requires focused and ongoing societal efforts to address historical and contemporary injustices; overcome economic, social, and other obstacles to health and health-care; and eliminate preventable health disparities (Office of Disease Prevention and Health Promotion n.d.).

#### Indigenous

Refers to people with origins in the original or earliest known inhabitants of an area, in contrast to groups that have settled, occupied, or colonized the area more recently in human history (National Institutes of Health 2024).

#### Intersectionality

How social and cultural categories (such as race, class, and gender) are linked. Interconnected structures and systems create inequality among people and populations based on social categories of difference (such as race, class, and gender) (Crenshaw 1991).

#### Minoritized

Refers to socially constructed groups who have been historically marginalized in society based on their racial, ethnic, sexual orientation, gender identity, or other social identity membership (Flanagin et al. 2021; National Institutes of Health 2024).

#### Preemption

Occurs when the action of a lower level of government is blocked or overridden by the authority of a higher level of government (Legal Information Institute n.d.).

#### Race and ethnicity

“Race and ethnicity are social constructs, without scientific or biological meaning” (Flanagin et al. 2021, p. 621). The Office of Management and Budget defines minimum categories for Federal data and statistics on race and ethnicity.

##### Race

- “American Indian or Alaska Native. A person having origins in any of the original peoples of North and South America (including Central America), and who maintains tribal affiliation or community attachment.
- Asian. A person having origins in any of the original peoples of the Far East, Southeast Asia, or the Indian subcontinent including, for example, Cambodia, China, India, Japan, Korea, Malaysia, Pakistan, the Philippine Islands, Thailand, and Vietnam.
- Black or African American. A person having origins in any of the Black groups of Africa. Terms such as ‘Haitian’ or ‘Negro’ [have been used] in addition to ‘Black or African American.’
- Native Hawaiian or Other Pacific Islander. A person having origins in any of the original peoples of Hawaii, Guam, Samoa, or other Pacific Islands.
- White. A person having origins in any of the original peoples of Europe, the Middle East, or North Africa” (Federal Register 1997a, p. 58789).

“Respondents shall be offered the option of selecting one or more racial designations” (Federal Register 1997a, p. 58789) (i.e., multiple race).

##### Ethnicity

- “Hispanic or Latino. A person of Cuban, Mexican, Puerto Rican, South or Central American, or other Spanish culture or origin, regardless of race. The term Spanish origin can be used in addition to Hispanic or Latino” (Federal Register 1997a, p. 58789).

#### Sexual orientation

The term sexual orientation refers to the community with which a person self-identifies, including lesbian, gay, or bisexual and those who may not self-identify as lesbian, gay, or bisexual (e.g., queer, questioning, two-spirit, asexual). This term does not refer to a person’s sex assigned at birth or to their gender identity (Merriam-Webster n.d.).

#### Social justice

The theory of social justice, from bioethicists Powers and Faden, posits that “social justice is concerned with human well-being … [which] is best understood as involving plural, irreducible dimensions” (Powers and Faden 2006, p. 15). These dimensions of well-being include “health, personal security, reasoning, respect, attachment, and self-determination” (Powers and Faden 2006, p. 16). Justice focuses on “securing and maintaining the social conditions necessary for a sufficient level of well-being in all of its essential dimensions for everyone” (Powers and Faden 2006, p. 50).

#### Tobacco products

Commercially marketed products made, containing, or derived from tobacco or containing nicotine from any source, including but not limited to cigarettes (including menthol cigarettes), cigars (including premium cigars, little cigars, and cigarillos), waterpipe or hookah tobacco, pipe tobacco, electronic cigarettes (e-cigarettes), heated tobacco products, smokeless tobacco, and other tobacco or nicotine products without an approved therapeutic purpose (Federal Register 2023).

#### Tobacco-related health disparities

“Differences in the patterns, prevention, and treatment of tobacco use; the risk, incidence, morbidity, mortality, and burden of tobacco-related illness that exist among specific population groups in the United States; and related differences in capacity and infrastructure, access to resources, and [exposure to secondhand tobacco smoke]” (Fagan et al. 2004, p. 211). The lived experiences of disparate groups—involving both social determinants of health (such as persistent poverty) and social injustices (such as targeted marketing)—have cumulative effects across the lifespan.

#### Tobacco-related health equity

Fair, equitable, and just opportunities and conditions for all people to live a healthy life, free from tobacco-related disease, disability, and death (CDC 2015).

### Appendix 1.2 Chronology of Key Events Related to tobacco-related Health Disparities

Table 1A.1 Chronology of key events related to tobacco-related health disparities

Year(s) | Events
1600s | Colonization of Indigenous lands and the repurposing of traditional or ceremonial tobacco into a commercial product begins, resulting in the disruption of cultural practices within Indigenous communities.
1600s | A substantial proportion of the wealth of the early colonies arises from the exportation of tobacco cultivated using labor of enslaved people of African descent (USDHHS 1998).
1850s | Tobacco factories in Virginia begin recruiting free African American and White women as workers. Black women worked as field laborers, and White women work in other parts of the industry (Janiewski 1985).
1850s | Black employees in the tobacco industry work in areas of production that are separate from White employees (Janiewski 1985).
1883 | The Code of Indian Offenses outlaws many traditional American Indian religious practices that incorporate ceremonial tobacco, including ghost and sun dances, the use of medicine men, funeral practices, and ritualized gift-giving ceremonies (Nez Henderson et al. 2022; National Geographic n.d.).
1887 | The Dawes Act of 1887 reduces American Indian lands by 65% and allots the remainder to the head of each American Indian family in parcels for farming or grazing (National Park Service n.d.). The barren lands that were allotted to Indigenous people made it difficult for them to self-sufficiently grow tobacco (Keep It Sacred n.d.; National Archives n.d.).
1890 | R.J. Reynolds helps to finance the establishment of Winston-Salem University, a historically Black university (Gardiner 2004).
1890–1930s | Tobacco advertisements feature racist and imperialist imagery to appeal to White consumers (Tobacco Tactics 2021; Stanford Research into the Impact of Tobacco Advertising 2022).
1920s | Tobacco advertising geared toward women begins with targeted messaging about smoking and slimness (USDHHS 2001).
1924 | Lloyd “Spud” Hughes of Mingo Junction, OH is credited with adding menthol to cigarettes (Fortune Magazine 1932; Trinkets & Trash n.d.).
1929 | American Tobacco Company organizes a group of women to march in an Easter parade in New York City while holding “torches of freedom” (i.e., cigarettes) (Brandt 1996; Truth Initiative 2016a).
1930s | About half of all persons in manufacturing positions in tobacco companies are African American (Yerger and Malone 2002).
1940s | Tobacco advertising geared toward Black people begins, as companies recognize African American people as potential consumers (Yerger and Malone 2002).
1940s | Tobacco companies place ads in Black newspapers with expectation of a “quid pro quo,” as disclosed in documents internal to the tobacco industry documents; newspapers run editorials that support the positions of tobacco companies (McCandless et al. 2012).
1943 | Black women workers strike at R.J. Reynolds, initiating a change in wages and work conditions (American Postal Workers Union 2014).
1947 | Black workers strike at R.J. Reynolds to protest wage inequities and working conditions (Encyclopedia Virginia 1947).
1950s | Tobacco companies establish relationships with organizations working to advance Black communities in exchange for economic support, marketing access, and political relations (Yerger and Malone 2002).
1953 | Through the Indian Termination Act enacted in 1953, followed by other policies through 1968, Congress (a) sought to abolish tribes, relocate American Indian people, and sell their land, resulting in relocation to urban areas; and (b) terminated federal obligations to tribes, including federal aid, services, and protections (Native Voices 1953).
1954 | Hammond and Horn, epidemiologists from the ACS, launch the Hammond-Horn Study and identify differences in tobacco use and lung cancer by SES, occupation, and rural-urban geography (Hammond and Horn 1954).
1964 | In January, the first Surgeon General’s report, Smoking and Health: Report of the Advisory Committee to the Surgeon General of the Public Health Service, outlines the nation’s major public health issues related to cigarette smoking. This report is the first major government report to assign a causal relationship between cigarette smoking and cancer (USDHEW 1964).
1978 | Indigenous people formally regain their ability to exercise their traditional religious practices without penalty with the passage of the American Indian Religious Freedom Act (American Indian Religious Freedom Act 1978; American Indian Religious Freedom Act Amendments of 1994 1994; Nez Henderson et al. 2022). This Act extends protections to “preserve for American Indians their inherent right to freedom to believe, express, and exercise the traditional religions.” Prior to enactment, Indigenous people could not perform public ceremonies with traditional tobacco (D’Silva et al. 2018; American Indian Health Service of Chicago n.d.).
1980s | Deloyd T. Parker, Jr., co-founder and executive director of SHAPE (Self-Help for African People through Education) Community Center in Houston, Texas, refuses to accept a $50,000 Kool Achiever Award (Center for the Study of Tobacco and Society n.d.b).
1980s | John Wiley Price, County Commissioner for District 3 of Dallas, Texas, is one of the first elected officials to denounce the cigarette companies and their advertising in neighborhoods with high concentrations of residents from minoritized population groups (Center for the Study of Tobacco and Society n.d.b).
1980s | Father Michael Pfleger, a Roman Catholic priest in Chicago, leads efforts with members of his church to deface tobacco and alcohol billboards. These efforts led the Chicago City Council to vote to remove such ads from the Auburn Gresham neighborhood, which is comprised largely of African American residents (McClory 2010; Chicago Tribune 2012; Center for the Study of Tobacco and Society n.d.b).
1980s–1990s | Robert C. Newberry (1990), a columnist for the Houston Post, writes several columns on the cigarette companies’ exploitation of the black community.
1980s–2000s | James G. Muhammad, a reporter for The Final Call published in Chicago by the Nation of Islam, writes hard-hitting articles against the tobacco industry (Muhammed 2006; Center for the Study of Tobacco and Society n.d.b).
1980 | Alberta Tinsley-Talabi seeks to ban tobacco and alcohol billboards in Detroit in 1989 when she serves on the City Council. She persuades Michigan Congressman John Conyers to introduce a measure in the U.S. House of Representatives to ban tobacco and alcohol billboards in neighborhoods with high concentrations of residents from minoritized population groups (Center for the Study of Tobacco and Society n.d.b; Michigan House Democrats n.d.).
1985 | Virginia L. Ernster, Associate Professor in the School of Medicine at the University of California–San Francisco, publishes the first paper to systematically study the tobacco industry’s targeted marketing to women (Ernster 1985).
1985 | The Surgeon General’s Report, The Health Consequences of Smoking: Cancer and Chronic Lung Disease in the Workplace, identifies differences in tobacco use based on occupational class (USDHHS 1985).
1988 | NCI publishes the Annotated Bibliography of Cancer-Related Literature on Black Populations, which includes a focus on tobacco-caused lung cancer (NCI 1988).
1988 | California is the first state to implement a comprehensive statewide tobacco control program (November 1988). The state passes Proposition 99, California Tobacco Tax and Health Promotion Act, which allows for a 25-cent tax on cigarettes and funding for tobacco control activities (Themba-Nixon et al. 2004). This initiative also launches the California Tobacco Control Program, which highlights pointed advocacy on priority populations as one key intervention to reduce tobacco-related health disparities (Roeseler and Burns 2010).
1989 | The National LCAT is establishes as a 501(c)(3) organization, the only national organization dedicated solely to reducing the harm caused by alcohol use and tobacco use in the Latino community through research, policy analysis, community education, and training (LCAT n.d.). Dr. Jeannette Noltenius serves as LCAT’s Executive Director for many years (Parker 2003; North American Quitline Consortium n.d.).
1989–1990 | Pathways to Freedom is developed at the Fox Chase Cancer Center in Philadelphia with funding from NCI and under the leadership of Dr. Robert G. Robinson. It is based on principles of community competence, which makes explicit the importance of history, culture, context, geography, literacy, language, positive imagery, salient imagery, multigenerational content, and diversity (Robinson et al. 2006).
1990s | Henry McNeil “Mandrake” Brown, Jr., a court reporter in Illinois, whitewashes billboards that promote tobacco and alcohol products in Chicago’s African American community (Heise 1996).
1990s | Brenda Bell Caffee leads the California African American Tobacco Education Network in developing nationally recognized model community initiatives and is a founding Elder of the National African American Tobacco Prevention Network. She creates the “Not in Mama’s Kitchen” Secondhand Smoke Eradication Program (Caffee, Caffee & Associates Public Health Foundation n.d.; Center for the Study of Tobacco and Society n.d.b).
1990s | Rev. Calvin Butts, pastor of the Abyssinian Baptist Church in Harlem, New York, leads efforts to whitewash tobacco and alcohol billboards located in Harlem and pickets the corporate headquarters of Philip Morris Companies in New York City (Associated Press 2022; Center for the Study of Tobacco and Society n.d.b; Encyclopedia.com n.d.).
1990s | Charyn D. Sutton, serves as media coordinator of the Uptown Coalition for Tobacco Control and Public Health, a contributing author to Pathways to Freedom, a founding member of the National Association of African Americans for Positive Imagery, and contributor to Tobacco Use Among U.S. Racial/Ethnic Minority Groups: A Report of the Surgeon General, which was published in 1998 (Sutton 2013; Center for the Study of Tobacco and Society n.d.b).
1990s | Sandra Headen, PhD, serves as teacher and researcher at the University of North Carolina Gillings School of Global Public Health where she develops pioneering, youth-led smoking cessation programs. She also serves as the first executive director of the National African American Tobacco Prevention Network (Center for the Study of Tobacco and Society n.d.b).
1990s | Yvonne Lewis works for the American Lung Association before joining the CDC in 1994. In addition to helping to develop national and international initiatives, she spearheads the policy that helps the Head Start program adopt systemwide smokefree policies (Center for the Study of Tobacco and Society n.d.b).
1990s | William S. Robinson is a founding member of the National African American Tobacco Prevention Network and serves as its Executive Director for many years (Center for the Study of Tobacco and Society n.d.b).
1990 | USDHHS launches Healthy People 2000, a comprehensive, nationwide health promotion and disease prevention framework to improve the health of all people in the United States. One of the three broad goals of Healthy People 2000 is to “reduce health disparities” (Office of Disease Prevention and Health Promotion 2021). This is the second iteration of the Healthy People objectives; Healthy People 1990, issued in 1979, did not have a specific goal to address health disparities.
1990 | R.J. Reynolds plans to launch a campaign in February in Philadelphia, Pennsylvania, to promote Uptown menthol cigarettes to increase their appeal to Black or African American people. One month before the launch, the proposed campaign sparks protests by community activists and major community-based and national organizations, including representatives from the Uptown Coalition for Tobacco Control and Public Health, ACS, and the Philadelphia branch of the NAACP. In response, R.J. Reynolds ceases production of Uptown cigarettes, and the targeted ads are never released (Ramirez 1990a,b).
1990 | The California Department of Health Services Tobacco Control Branch begins funding tobacco control organizations representing various minoritized racial and ethnic populations to enact tobacco control programs tailored to their stakeholders and populations of interest. The first organization funded is APITEN (Asian & Pacific Islander American Health Forum 1994; Asian and Pacific Islander Tobacco Education Network 2004).
1990 | The California Department of Health Services, Tobacco Control Branch launches the longest running antitobacco program in the nation. The media campaign is the first to reach diverse populations with paid advertisements in six languages: Cantonese, English, Korean, Mandarin, Spanish, and Vietnamese (California Department of Public Health 2017).
1991 | NCI (1991) publishes its first Smoking and Tobacco Control Monograph, Strategies to Control Tobacco Use in the United States: A Blueprint for Public Health Action in the 1990s. This volume reports differences in smoking prevalence and lung cancer mortality by race and gender.
1991 | Rev. Jesse W. Brown Jr. and Henry McNeil “Mandrake” Brown, Jr., co-found the National Association of African Americans for Positive Imagery, which leads efforts to counter the promotion of unhealthy tobacco products targeted to African Americans (Heise 1996; Center for the Study of Tobacco and Society n.d.b).
1991 | On May 20, APITEN convenes its first statewide conference with the main goal of mobilizing other tobacco control advocates to assist in passing tobacco tax legislation that would ensure sustained funding to address tobacco-related health disparities (Asian and Pacific Islander Tobacco Education Network 1991).
1991; 2003 | In 1991, CDC’s Office on Smoking and Health adopts Pathways to Freedom as state-of-the-art material to help African American people successfully quit smoking. In 2003, the Office on Smoking and Health revises Pathways to Freedom, which undergoes an extensive qualitative evaluation based on a national sample of people who smoked, practitioners, and stakeholders (Robinson et al. 2006)
1997 | CDC releases a funding announcement of $1 million in June to assist organizations in establishing programs that seek to reduce tobacco-related health disparities, as set forth in the Healthy People 2000 initiative, for populations, including African American, Hispanic, Asian and Pacific Islander, and American Indian and Alaska Native people; youth; women; and lower wage workers (Federal Register 1997b). This marks the beginning of CDC’s funding of what is now known as the Consortium of National Networks to Impact Populations Experiencing Tobacco-Related and Cancer Health Disparities. This initiative provided funding to establish the National African American Tobacco Prevention Network (Devex n.d.).
1997 | In May, leaders in tobacco control issue the Communities of Color Statement to policymakers on behalf of minoritized racial and ethnic population groups to ensure that their needs will be met using MSA funds (see 1998 in this table) when they are allocated. The tobacco control leaders are concerned that lower income people who smoke in their respective communities will experience an increased financial burden because of the higher costs of cigarettes and will not reap the benefits from the settlement monies (Themba-Nixon et al. 2004).
1997 | Dr. Gary King, sociologist, publishes the seminal paper titled, “The Concept of Race in Smoking: A Review of Research on African Americans” (King 1997). This paper discusses the race concept as used by researchers, uncritically, who have studied the smoking behavior of African American people but may not understand the dimension of race as a social construct (King 1997). Dr. King is the first to use the term racially classified social groups in the context of smoking (Fernander 2007).
1998 | Surgeon General Dr. David Satcher releases Tobacco Use Among U.S. Racial/Ethnic Minority Groups—African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, Hispanics: A Report of the Surgeon General. It is the first report in the series to specifically address tobacco-related health disparities in four racial and ethnic groups. The report details the prevalence of tobacco use among the different groups and identifies gaps in research concerning tobacco-related health disparities (USDHHS 1998).
1998 | In Brown v. Philip Morris, civil rights activists file a class action lawsuit against major tobacco companies, citing the targeted advertising of mentholated products to Black or African American people as a violation of the Civil Rights Act and the 13th and 14th Amendments. The activists include the Uptown Coalition for Tobacco Control and Public Health, a community-based advocacy group; Rev. Jesse W. Brown Jr.; and the National Association of African Americans for Positive Imagery. The lawsuit calls for the end of the production, sale, and promotion of tobacco products containing menthol. It also seeks to establish tobacco education and cessation programs for Black or African American people (National Association of African Americans for Positive Imagery 1998). In September 1999, U.S. District Judge John R. Padova dismisses the lawsuit. On appeal, in a split decision announced on May 18, 2001, the 3rd Circuit Court of Appeals upholds the dismissal by the lower federal court (National Association of African Americans for Positive Imagery 2001).
1998 | Four states (Florida, Minnesota, Mississippi, and Texas) reach settlements with the tobacco industry to recover healthcare costs associated with tobacco-related illnesses. Minnesota is the only state lawsuit to go to trial. In addition to a large monetary award and public health provisions, the Minnesota settlement requires defendant tobacco companies to publicly disclose enormous numbers of documents produced during the discovery process and create two publicly accessible document depositories, including documents revealing the industry’s targeted marketing of disparate communities. This disclosure is credited as changing the tobacco control landscape (Hurt et al. 2009).
1998 | In November, the remaining 46 states, 4 U.S. territories, the Commonwealth of Puerto Rico, and the District of Columbia enter into the MSA with the five largest tobacco companies in the nation: Philip Morris USA Inc., R.J. Reynolds Tobacco Company, Brown & Williamson Corporation, and Lorillard Tobacco Company (Public Health Law Center 1998, 2019; USDHHS 2000). This agreement is entered to recover billions in healthcare costs associated with tobacco-related illnesses, and particularly with Medicaid expenditures. The MSA restricts some of the tobacco industry’s marketing strategies; requires tobacco companies to release thousands of internal documents and make them accessible to the public; and provides funds to create the American Legacy Foundation, a national tobacco education and prevention organization.
1998 | Dr. Alan Blum, Professor at the University of Alabama, directs the Center for the Study of Tobacco and Society, which has the largest collection of original documents, artifacts, images, and reports on the tobacco industry and the antismoking movements. He pioneers research on the tobacco industry’s targeted marketing to women and minoritized groups (Center for the Study of Tobacco and Society n.d.a).
1999 | In the summer, two lawsuits are filed against the tobacco companies settling in the MSA. The first lawsuit seeks reimbursement and payment of punitive damages to treat tobacco-related illnesses for 34 American Indian tribes since 1962. The second lawsuit lodges a complaint that tobacco companies are targeting American Indian people, causing a public health issue, and purposely excluding tribes from MSA negotiations. Both cases are dismissed because the court ruled that the tribes had no right to recover federal monies spent on healthcare (Brown & Williamson 2004; Themba-Nixon et al. 2004).
2000 | U.S. Senate passes the Minority Health and Health Disparities Research and Education Act of 2000 (2000). Title I of this Act (“Improving Minority Health and Reducing Health Disparities Through National Institutes of Health; Establishment of National Center”) establishes the National Center on Minority Health and Health Disparities to conduct and support research, training, and the dissemination of information and other programs that focus on health conditions of minoritized racial and ethnic groups and other populations affected by health disparities (American Legacy Foundation n.d.; National Institute on Minority Health and Health Disparities n.d.).
2000 | In January, USDHHS launches Healthy People 2010, a comprehensive, nationwide health promotion and disease prevention framework to improve the health of all people in the United States. The two overarching goals are to increase quality and years of healthy life and to eliminate health disparities (CDC 2015b). Subsequent initiatives, including Healthy People 2020 (launched in 2010) and Healthy People 2030 (launched in 2020) also include goals related to health equity, elimination of disparities, and social determinants of health (Office of Disease Prevention and Health Promotion 2021).
2000 | In December, the Office of the Surgeon General releases its 26th report on tobacco, Reducing Tobacco Use: A Report of the Surgeon General, which concludes that there is a need to addresses tobacco-related health disparities and emphasizes the importance of reducing the negative effects of tobacco on the health of various populations (USDHHS 2000).
2000 | Sharon Eubanks, JD, serves as lead counsel on behalf of the United States in United States v. Philip Morris USA, et al. This federal tobacco litigation is the largest civil Racketeer Influenced and Corrupt Organizations (RICO) enforcement action in history (Cornell Law School n.d.).
2001 | NCI appoints Dr. Harold Freeman as the first Director of the Center to Reduce Cancer Health Disparities (Freeman 2003).
2001 | The American Legacy Foundation (n.d.) launches its Priority Populations Initiative, which provides $25 million to 83 grantees to fund programs with the goal of reducing tobacco-related health disparities and preventing tobacco use among high-risk populations. The initiative funds cessation services and education programs on the harms of tobacco use (Healton et al. 2004).
2002 | In February, LCAT holds the first National Hispanic/Latino Conference on Tobacco Prevention and Control (University of Southern California 2002).
2002 | The Campaign for Tobacco-Free Kids grants funding to the Asian Pacific Partners for Empowerment, Advocacy, and Leadership to create the Mobilizing Asian American and Pacific Islander Communities on the Tobacco Settlement toolkit. The toolkit encourages states to increase their efforts to educate Asian American and Pacific Islander people about the risks of tobacco use (Themba-Nixon et al. 2004).
2002 | The National Conference on Tobacco and Health Disparities convenes in December, marking the first gathering of experts in tobacco control to discuss research agendas to combat tobacco-related health disparities. The outcomes from this conference yield more than 100 recommendations for future research. These recommendations continue to inform tobacco-related health disparities research today (Fagan et al. 2004).
2002 | On March 21–22, CDC and NCI host The First Conference on Menthol Cigarettes: Setting the Research Agenda, in Atlanta, GA. This meeting is co-chaired by Pamela Clark, PhD, and Phillip Gardiner, Dr.PH, who led efforts to evaluate the present state of the science about the health implications of adding menthol to cigarettes and about setting the priorities for future studies on the health effects of menthol cigarettes. The conference results in a report and the first supplement issue on menthol cigarettes, which is published in Nicotine & Tobacco Research (2004).
2003 | In October, the Tobacco-Related Disease Research Program and other California tobacco control leaders cosponsor the “Priority Populations Conference: Weaving Our Message—United Against Tobacco Abuse.” The main goal of this conference is to plan for a future of protecting priority populations from tobacco-related health issues (University of California 2003; Themba-Nixon et al. 2004).
2003 | NCI and the American Legacy Foundation partner to establish TReND, a network of 21 core members and scientists who work across various disciplines. The mission of this network is to “eliminate tobacco-related health disparities through transdisciplinary research … [that] informs public policy” (Clayton 2006, p. ii3; Okuyemi et al. 2015).
2003 | A question that assesses menthol smoking status is added to TUS-CPS, an effort led by Dr. Deirdre Lawrence Kittner (NCI 2022b).
2003 | The TUS-CPS is translated into Chinese, Khmer, Korean, and Vietnamese, an effort led by Dr. Deirdre Lawrence Kittner (NCI 2022a).
2004 | Brown & Williamson launches the Kool Mixx marketing campaign. The campaign uses images of disc jockeys and rappers on product packaging. Community activists argue that the campaign and its imagery target menthol products to Black or African American people, specifically Black or African American youth. In May, attorneys general in 29 states send a letter to Brown & Williamson urging it to cease production and promotion of the product, citing a violation of the MSA. Kool Mixx cigarette packages are recalled after the New York Supreme Court issues a restraining order to halt the promotion of the campaign (New York State Attorney General 2004; Hafez and Ling 2006).
2004 | Just 5 months after the Kool Mixx controversy, R.J. Reynolds is pressured by the state attorney general of Hawai‘i, Governor of Hawai‘i, and Mayor of the Island of Kaua‘i to discontinue sales of Camel Exotic Blends, a product line targeting Native Hawaiian people. R.J. Reynolds ceases production of the cigarettes and the production of all Camel, Kool, and Salem cigarettes that contain characterizing flavors, except for menthol, in 2006 (American Lung Association 2006; Brnovich 2006).
2004 | Members of TReND launch the Low Socioeconomic Status Women and Girls Project. The goal of the project is “to stimulate new research, review existing research, and, as a result of its findings, inform the development and implementation of policies and programs that may reduce tobacco use among low socioeconomic status women and girls.” This project is the first to address the effects of tobacco policies on this population (NCI 2012).
2005 | In September, TReND hosts “Tobacco Control Policies: Do They Make a Difference for Low SES Women and Girls?” Attendees at the meeting examine new data on the effects of tobacco control policies on women and girls from lower SES groups. After the meeting, TReND publishes two special journal issues to address disparities in these populations (Greaves et al. 2006; McLellan and Kaufman 2006; NCI 2012).
2005 | NCI’s Center to Reduce Cancer Health Disparities awards $95 million over a 5-year span to the Community Networks Program. The program funds 25 networks, whose goals include reducing cancer health disparities in minoritized racial and ethnic groups and other underserved communities. The funding permits networks to address tobacco-related health disparities in these communities through education, community outreach, and research efforts (Tong et al. 2015).
2005 | The ATOD Section of the APHA awards its Lifetime Achievement Award to Charyn D. Sutton, president of the Onyx group; the award is presented posthumously to her mother for “… commitment to eliminate health disparities in minoritized communities” (University of North Carolina at Chapel Hill Program for Ethnicity n.d.).
2006 | Drs. Pebbles Fagan and Donna Vallone, co-chairs of TReND, formally propose establishing a tobacco and health disparities committee to Dr. Ellen Gritz, president of SRNT. The researchers envision expanding the focus of SRNT’s Special Populations Subcommittee to include the advancement of research on tobacco-related health disparities to bring it to the forefront of the scientific community. SRNT’s Tobacco and Health Disparities Committee commences with inaugural chairs Drs. Fagan and Dennis Trinidad (Okuyemi et al. 2015).
2006 | On August 17, a district court judge in U.S. v. Philip Morris USA, finds major U.S. tobacco companies liable for violating the Racketeer Influenced and Corrupt Organizations Act. The companies conspired to deceive the American public about the dangers of tobacco products and about their role in designing and marketing highly addictive products and distorting scientific evidence. Included in Judge Kessler’s decision are findings about the industry’s knowledge of consumer perceptions of menthol and how certain companies targeted their menthol marketing to better reach certain population groups. The court orders the companies to post corrective statements in newspapers, on TV, on cigarette packages, in retail stores, and online (United States v. Philip Morris USA, Inc. 2006; Tangari et al. 2010; Public Health Law Center n.d.e).
2006 | TReND holds the LGBT of Color Sampling Methodology meeting in Washington, D.C., on September 15. The effort seeks to identify gaps in tobacco control research and to conceptualize and plan future research related to the LGBT community and their disparate health outcomes (Buchting et al. 2009).
2007 | In June, Maine becomes the first state to pass a law banning the sale of cigars with characterizing flavors other than tobacco, menthol, clove, coffee, nuts, or peppers, effective July 1, 2009 (Maine Legislature 2007). The law is amended in April 2010 so that tobacco flavor is the only allowable flavor in non-premium cigars. It allows the sale of flavored premium cigars and some preexisting flavored non-premium cigars (Maine Legislature 2010).
2008 | In June, seven former secretaries of USDHHS, one former Surgeon General, and one tobacco control advocate write to urge Congress to ban menthol in the impending Family Smoking Prevention and Tobacco Control Act of 2009 (Tobacco Control Act). The letter details the high prevalence of menthol cigarette use among Black or African American people compared with other racial and ethnic groups (The New York Times 2008).
2008 | Carol McGruder, Dr. Phillip Gardiner, and Dr. Valerie Yerger help to found the AATCLC in California (African American Tobacco Control Leadership Council n.d.b).
2009 | On June 22, President Barack Obama signs into law the Family Smoking Prevention and Tobacco Control Act of 2009. This seminal legislation grants FDA regulatory control of the manufacturing, distribution, and marketing and advertising of tobacco products. It prevents the sale of flavored cigarettes, excluding tobacco and menthol flavors, and gives FDA the authority to (a) require health warnings on smokeless tobacco products, (b) promulgate a regulation requiring pictorial health warnings on cigarette packages, (c) require a premarket review, and (d) issue product standards (which could be standards regarding ingredients or constituents). This legislation creates FDA’s Center for Tobacco Products and the TPSAC, a 12-member scientific advisory committee representing diverse expertise (Tobacco Control Legal Consortium 2009; FDA 2020).
2010 | On March 23, President Obama signs the Patient Protection and Affordable Care Act (ACA) into law. Among other achievements, this legislation establishes the Prevention and Public Health Fund, which provides funds to reduce and prevent tobacco use. The ACA also expands coverage for tobacco cessation that is aimed at decreasing the prevalence of tobacco use, especially among people of lower SES who use tobacco. The expansion of Medicaid also provides smoking cessation benefits to more citizens with lower incomes. The ACA allows tobacco dependence to be treated as a substance use disorder under some circumstances (Patient Protection and Affordable Care Act 2010; Tobacco Control Legal Consortium n.d.).
2010 | As part of the ACA, the National Center on Minority Health and Health Disparities (n.d.) is designated as an NIH Institute and charged with leading scientific research to improve health among minoritized racial and ethnic groups and reduce health disparities.
2010 | NCI, CDC’s Office on Smoking and Health, American Legacy, and TReND collaborate to publish two special journal issues (Addiction [2010] and Nicotine & Tobacco Research [2010]) to inform the evidence base related to the Congressionally mandated report on the public health impact of menthol. The FDA TPSAC uses the results from the papers to inform the writing and conclusions of the report published in 2011 (Tobacco Products Scientific Advisory Committee 2011). FDA uses the research to inform the writing and conclusions of the report published in 2013 (FDA n.d.).
2011 | In February, Lorillard and R.J. Reynolds file a lawsuit challenging the TPSAC, which was constituted to, among other things, examine menthol cigarettes under the Tobacco Control Act of 2009. The companies claim that three members of TPSAC had conflicts of interest and urge the court not to permit FDA to use the TPSAC’s forthcoming report on menthol to inform decision making about menthol cigarettes. In 2014, the District Court for the District of Columbia ruled in favor of the tobacco companies but that decision was later reversed and vacated (Public Health Law Center n.d.b)
2011 | The TPSAC releases its report on menthol concluding that the availability of menthol cigarettes has a negative impact on public health and that banning menthol cigarettes would benefit public health. At the TPSAC public meeting on January 11, Mark Stuart Clanton, MD, MPH, former Deputy Director of the NCI and past member of the first TPSAC and its Menthol Subcommittee, reads the final TPSAC conclusions on the public health impact of menthol in cigarettes (Center for Tobacco Products 2011; TPSAC 2011).
2011 | SRNT and its Health Disparities Committee transform into a network. From this point on, the network meets annually during the larger SRNT conferences (Okuyemi et al. 2015).
2011 | NCI (2011) publishes Guía: Viva de Forma más Saludable Para Usted y su Familia, Deje de Fumar hoy Mismo (Guide: Live Healthier for You and Your Family Quit Smoking Today), the first nationally distributed evidence-based, self-help cessation-focused material tailored for Hispanic or Latino populations.
2011 | Delmonte Jefferson becomes the director of the National African American Tobacco Prevention Network, a national organization whose mission is to “facilitate the development and implementation of comprehensive and community competent public health programs to benefit communities and people of African descent” (Center for the Study of Tobacco and Society n.d.b; National African American Tobacco Prevention Network n.d.).
2012 | Campaign for Tobacco-Free Kids publishes How Big Tobacco and Convenience Stores Partner to Market Tobacco Products and Fight Life-Saving Policies. The report details the various ways in which tobacco companies continue to use convenience stores to help promote their products in the form of point-of-sale advertising. This form of advertising targets children and lower income communities among minoritized racial and ethnic groups, specifically where these types of stores are most prevalent (Campaign for Tobacco-Free Kids 2012).
2012 | In March, the Surgeon General publishes Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. This report includes data and other information on disparities in tobacco use among young people of color and youth of lower SES, as well as geographical differences in health outcomes among youth. Because of limited data, findings on LGBT youth are not presented (USDHHS 2012).
2012 | In March, CDC launches Tips From Former Smokers, the first national antitobacco campaign sponsored by a federal agency. The campaign is designed to reach people from multiple racial and ethnic, SES, sexual orientation and gender identity, and age groups who do not smoke and who used to smoke (CDC 2018).
2012 | Through funding from CDC, California launches the Asian Smokers’ Quitline, the first quitline to provide culturally appropriate smoking cessation services to Cantonese-, Mandarin-, Korean-, and Vietnamese-speaking populations nationwide (Kuiper et al. 2015).
2013 | The NHIS adds a question to capture self-reported sexual orientation (National Center for Health Statistics n.d.). Scout, PhD, advocated for many years to add this question that would help quantitatively document the known disparities in smoking among LBGT communities (National LGBT Cancer Network n.d.).
2013 | FDA issues an advanced notice of proposed rulemaking and request for comments on menthol in cigarettes and other tobacco products (Federal Register 2013).
2013 | Delta Sigma Theta Sorority, Inc., becomes the first African American organization to adopt a national resolution urging FDA to ban menthol cigarettes (Delta Sigma Theta Sorority 2017).
2013 | Eighteen organizations representing various populations at risk for tobacco-related morbidity and mortality collectively issue a citizen petition to FDA requesting a federal ban on the sale of menthol-flavored cigarettes (Tobacco Control Legal Consortium 2013).
2013 | AACR and ASCO are among the first professional organizations focused on cancer research to submit a letter to FDA urging FDA to ban menthol in cigarettes (American Association for Cancer Research and American Society of Clinical Oncology 2013).
2013 | In December, the Chicago City Council passes an ordinance banning the sale of menthol cigarettes within 500 feet of schools, making Chicago the first U.S. city to regulate the sale of menthol cigarettes (Freiberg 2015; Tobacco Control Legal Consortium 2016).
2014 | In Cynthia Robinson v. R.J. Reynolds Tobacco Company, private citizen Cynthia Robinson sues R.J. Reynolds for the death of her husband, who developed lung cancer from smoking menthol cigarettes. Ms. Robinson asserts that R.J. Reynolds did not adequately warn customers about the addictiveness of nicotine and the significant risk of lung cancer. The court rules in favor of Ms. Robinson, awarding her $23 billion in damages, which were later reduced to $16.9 million (Robles 2014; The National Trial Lawyers n.d.).
2015 | In May, FDA launches the Fresh Empire campaign. The campaign is tailored to attract Black or African American, Hispanic, and Asian American and Pacific Islander youth who identify with hip-hop culture. The campaign promotes the healthy connections between the hip-hop lifestyle and living tobacco-free (FDA 2022a).
2015 | In August, National Jewish Health launches the AICTP to provide American Indian people from several states with remote counseling on tobacco cessation. The program features American Indian smoking cessation coaches and aims to reduce the prevalence of commercial tobacco use in this underserved population (National Jewish Health 2015).
2015 | The AICTP quitline, 1-855-5AI-QUIT (1-855-524-7848), is established in Minnesota and serves 14 states (AICTP n.d.).
2015 | CDC publishes the Best Practices User Guide: Health Equity in Tobacco Prevention and Control (CDC 2015a).
2016 | On January 15, the U.S. Court of Appeals for the District of Columbia rules against Lorillard and R.J. Reynolds in their 2011 lawsuit challenging the TPSAC menthol report. The appellate court finds that the companies’ allegations of harm were speculative and overturned a lower court’s order that had dissolved TPSAC and had mandated that FDA could not use the report. The court ordered the reconstitution of TPSAC (Public Health Law Center n.d.c).
2016 | On July 19, the NAACP adopts, at its national conference in Cincinnati, Ohio, a national resolution to urge FDA to ban menthol cigarettes. The resolution, which was ratified on October 15 by the NAACP National Board of Directors, calls on NAACP chapters to support local policy efforts to restrict the sale of menthol cigarettes and other flavored tobacco products, such as little cigars, cigarillos, and the flavored juices used in electronic nicotine devices (NAACP n.d.).
2016 | The Truth Initiative joins the AATCLC in an open letter to former President Barack Obama urging FDA to ban menthol in combusted cigarettes (African American Tobacco Control Leadership Council 2016; Truth Initiative 2016b).
2016 | On May 10, FDA announces its final deeming rule, which extends FDA’s regulatory authority to all tobacco products, including future tobacco products. FDA now has the power to restrict the sale of tobacco products, including cigars and e-cigarettes and their parts and components, to youth and to issue product standards to newly deemed products (Federal Register 2016a).
2016 | In December 2016, the U.S. Department of Housing and Urban Development issues a final rule that requires all PHAs that provide lower income, conventional public housing to implement smokefree policies in their facilities by July 30, 2018. Policies must prohibit residents from smoking indoors on any PHA properties or within 25 feet of a PHA building (Federal Register 2016b; U.S. Department of Housing and Urban Development 2016).
2016 | FDA’s The Real Cost campaign is expanded to include boys living in rural areas. The goal of the expanded campaign is to educate young people on the dangers of smokeless tobacco use (FDA 2019).
2016 | FDA launches the This Free Life campaign. The campaign is designed to prevent and reduce tobacco use among LGBTQI+ young adults who occasionally smoke cigarettes (FDA 2022b).
2017 | In June, the board of supervisors in San Francisco, California, bans the sale of all flavored tobacco products, including mentholated cigarettes. R.J. Reynolds petitions against this ban and requests a public vote (Swan 2017). On June 5, 2018, nearly 70% of San Francisco residents vote in favor of upholding the ban (City and County of San Francisco 2018). San Francisco begins enforcing these sales restrictions in April 2019.
2017 | In July, the city council in Oakland, California, restricts the sale of mentholated tobacco products, except in specialty stores (Oakland City Council 2017; Tadayon 2017). This exemption was later removed.
2017 | NCI publishes Tobacco Control Monograph 22, A Socioecological Approach to Addressing Tobacco-Related Health Disparities, which calls for individual- to systems-level interventions and policies to be key components of comprehensive tobacco control, prevention, and treatment. This is the first monograph to focus specifically on tobacco-related health disparities (NCI 2017).
2017 | Truth Initiative issues a report called Tobacco Nation: An Ongoing Crisis, which highlights states where the prevalence of tobacco use exceeds 20%, where residents are relatively poor, and where healthcare infrastructure is poor (Truth Initiative 2019).
2018 | On March 21, FDA publishes an advanced notice of proposed rulemaking, with a call for data, research, and comments regarding the role of flavors in tobacco products. FDA plans to use the information gained from the call to inform its decisions on regulating flavored tobacco products in the future (Federal Register 2018).
2018 | Rev. Jesse W. Brown, Jr., outlines cigar manufacturer Swisher International, Inc.’s aggressive marketing to African American people in the form of concerts and in-store entertainment (Center for the Study of Tobacco and Society n.d.b).
2018 | In May, ClearWay Minnesota funds the American Indian Quitline Program, a tobacco cessation quitline dedicated to serving American Indian people who live in Minnesota (North American Quitline Consortium 2018).
2018 | In July, the City Council in Richmond, California, votes to prohibit the retail sale of menthol and flavored tobacco products within city limits, following actions in other California cities (e.g., Berkeley) and counties (Contra Costa and Alameda) (Tadayon 2018).
2018 | The San Francisco Board of Supervisors bans the sale of flavored tobacco products (Center for the Study of Tobacco and Society n.d.b).
2019 | Rod Lew receives the Andre Stanley Memorial Health Equity Award from the APHA. The award honors an individual who has contributed to public health efforts to build health equity and reduce health disparities in the area of substance use. Lew is recognized for his leadership in addressing the disproportionate impact of commercial tobacco on Asian American and Native Hawaiian and Pacific Islander communities and other priority populations. Andre Stanley, who died in 2017, worked with the ASSIST study, the APHA, and FDA to advocate for tobacco prevention and control among diverse population groups (North American Quitline Consortium 2019).
2020 | Massachusetts becomes the first state to prohibit the sale of all flavored tobacco products, including menthol cigarettes, effective on June 1 (Campaign for Tobacco-Free Kids 2023).
2020 | California enacts a statewide law prohibiting the sale of all flavored tobacco products (Campaign for Tobacco-Free Kids 2023). Tobacco companies delay implementation until a referendum vote in 2022 (New York Times 2022).
2020 | Policies of AMA—under the leadership of Dr. Patrice Harris, first African American president of AMA—recognize race as a social, not biological, construct (American Medical Association 2020; American Medical Women’s Association n.d.).
2020 | On June 17, the AATCLC and ASH file a lawsuit against FDA in the Northern District of California alleging an unreasonable delay on the part of the agency in banning menthol in cigarettes. The two groups request several forms of relief from the court, including an order requiring FDA to respond to the citizen petition and an order requiring FDA to reevaluate the tobacco product standards. AMA joined the lawsuit as a plaintiff on September 3; and NMA joined AATCLC, ASH, and AMA as plaintiffs on December 3 (Action on Smoking & Health 2020).
2021 | CDC Director Dr. Rochelle Walensky declares racism to be a serious public health threat and announces efforts to advance science, invest in communities, foster diversity and inclusion, catalyze public and scientific discourse around racism and health, and be accountable for progress (CDC 2021).
2021 | The University of Illinois Chicago School of Public Health names the Andre Gilmore Stanley DrPH Scholarship in honor of Stanley and his legacy of fighting racism, inequities, and advocating for tobacco control in communities. In 2019, APHA also named the Andre Stanley Memorial Health Equity Award to honor his legacy and years served in APHA ATOD (University of Illinois Chicago School of Public Health 2021).
2021 | The Public Health Law Center and AATCLC, among other groups, file on January 14 a supplement to the citizen petition to FDA to prompt FDA to take action related to menthol in cigarettes (Public Health Law Center n.d.a).
2021 | On January 20, President Biden signs Executive Order 13985, Advancing Racial Equity and Support for Underserved Communities Through the Federal Government, which charged the government to address inequities in policies and programs by “[pursuing] a comprehensive approach to advancing equity for all, including people of color and others who have been historically underserved, marginalized, and adversely affected by persistent poverty and inequality” (Federal Register 2021).
2021 | On April 29, FDA responds to the citizen petition in a letter, which indicates that the agency plans to grant the petition and issue a proposed rule prohibiting menthol in cigarettes (Action on Smoking & Health 2021; Nelson 2021).
2022 | FDA issues two proposed rules on April 28, indicating that the agency plans to remove menthol from cigarettes (Federal Register 2022a) and all flavors (except tobacco flavor) from cigars (Federal Register 2022b), but those rules have not been finalized.
2022 | Navajo Nation casinos and public places become smokefree on February 5. The legislation was signed by Navajo Nation President Jonathan Nez in November 2021 (Smokefree Casinos 2021).
2022 | Dr. Pebbles Fagan receives the President’s Award from SRNT (n.d.), recognizing her lifetime work to advance research on tobacco-related health disparities.
2022 | Dr. Patricia Nez Henderson is the first Indigenous woman elected President of SRNT. Dr. Nez Henderson is a member of the Diné (Navajo) tribe and has worked for years to conduct participatory research and advocate for policies that protect Indigenous communities (Navajo-Hopi Observer 2022).
2022 | On September 28–30, the third meeting on menthol cigarettes is organized by the AATCLC and convenes in Washington, DC (African American Tobacco Control Leadership Council n.d.a).
2022 | On November 8, 2022, California voters overwhelmingly approve Proposition 31, a ballot measure on a 2020 law prohibiting the sale of all flavored tobacco products, including menthol cigarettes (New York Times 2022).
2023 | On February 16, President Biden signs Executive Order 14091, Further Advancing Racial Equity and Support for Underserved Communities Through the Federal Government, reaffirming the government’s commitment to take additional action to “combat discrimination and advance equal opportunity, including by redressing unfair disparities and removing barriers to Government programs and services” (Federal Register 2023).
2023 | CDC announces a new five-year, $15 million initiative to help increase adoption, implementation, and enforcement of policies prohibiting the sale of menthol and other flavored tobacco products and increase awareness of cessation services and coverage options among populations experiencing tobacco-related disparities in order to accelerate smoking cessation (CDC 2023).
2024 | On January 8, the Supreme Court declines to hear challenges from tobacco companies and retailers to California’s restrictions on the sales of flavored tobacco products, in which the companies and retailers argued that the Tobacco Control Act preempted the state law (Public Health Law Center n.d.d).

Notes:AACR = American Association for Cancer Research; AATCLC = African American Tobacco Control Leadership Council; ACA = Patient Protection and Affordable Care Act; ACS = American Cancer Society; AICTP = American Indian Commercial Tobacco Program; AMA = American Medical Association; APHA = American Public Health Association; APITEN = Asian & Pacific Islander Tobacco Control Education Network; ASCO = American Society of Clinical Oncology; ASH = Action on Smoking & Health; ASSIST = American Stop Smoking Intervention Study; ATOD = Alcohol, Tobacco, and Other Drugs; CDC = Centers for Disease Control and Prevention; FDA = U.S. Food and Drug Administration; LCAT = National Latino Council on Alcohol and Tobacco Prevention; LGBTQI+ = lesbian, gay, bisexual, transgender, queer, and intersex; MSA = Master Settlement Agreement; NAACP = National Association for the Advancement of Colored People; NCI = National Cancer Institute; NHIS = National Health Interview Survey; NIDA = National Institute on Drug Abuse; NIH = National Institutes of Health; NMA = National Medical Association; NUL = National Urban League; PHA = Public Housing Agency; SES = socioeconomic status; SRNT = Society for Research on Nicotine & Tobacco; TPSAC = Tobacco Products Scientific Advisory committee; TReND = Tobacco Research Network on Disparities; TUS-CPS = Tobacco Use Supplement to the Current Population Survey; UNCF = United Negro College Fund; USDHEW = U.S. Department of Health, Education, and Welfare; USDHHS = U.S. Department of Health and Human Services.

### References

Action on Smoking & Health. American Medical Association (AMA) joins AATCLC & ASH in lawsuit against FDA [press release], September 3, 2020; <https://ash.org/ama-joins-lawsuit-against-fda/>; accessed: August 5, 2022.
Action on Smoking & Health. Joint statement: the FDA agrees to ban menthol, to protect African Americans [press release], April 29, 2021; <https://ash.org/menthol/>; accessed: August 5, 2022.
Addiction. Special issue: The role of mentholated cigarettes in smoking behaviors in United States populations. Addiction 2010;105(s1):1–140.
African American Tobacco Control Leadership Council. Letter asking President Barack Obama to direct the FDA to issue a proposed rule to remove all flavored tobacco products, including mentholated cigarettes, from the marketplace [letter], August 11, 2016; <http://files.constantcontact.com/199ccd27001/002cbbfb-061f-4cff-947e-b814173c14a3.pdf>; accessed: June 30, 2022.
African American Tobacco Control Leadership Council. 3rd National Menthol Conference: finishing the fight! [announcement], n.d.a; <https://www.savingblacklives.org/event-details/mentholconference2022>; accessed: November 17, 2022.
African American Tobacco Control Leadership Council. About [AATCLC], n.d.b; <https://www.savingblacklives.org/about>; accessed: November 17, 2022.
American Association for Cancer Research and American Society of Clinical Oncology. Re: Docket No. FDA-2013-N-0521, menthol in cigarettes, tobacco products; request for comments [letter], November 22, 2013; <https://www.aacr.org/wp-content/uploads/2019/11/AACR-ASCO_Comments_on_FDA_Menthol_ANPRM_FINAL___F3F578.pdf>; accessed: June 30, 2022.
American Indian Commercial Tobacco Program. About program, n.d.; <https://aiquitline.com/en-US/About-Program>; accessed: August 5, 2022.
American Indian Health Service of Chicago. Four sacred medicines: the natural gifts, ceremony and healing powers of traditional Native American medicines, n.d.; <https://aihschgo.org/four-sacred-medicines/>; accessed: November 14, 2022.
American Legacy Foundation. Priority Populations Initiative: Breaking New Ground and Building Capacity in Cultural Tailoring. Washington (DC): American Legacy Foundation, n.d.
American Lung Association. From Joe Camel to Kauai Kolada—The Marketing of Candy-Flavored Cigarettes, May 2006; <http://www.lungusa2.org/slati/reports/CandyFlavoredUpdatedAlert.pdf>; accessed: February 19, 2019.
American Medical Association. New AMA policies recognize race as a social, not biological, construct [press release], November 16, 2020; <https://www.ama-assn.org/press-center/press-releases/new-ama-policies-recognize-race-social-not-biological-construct>; accessed: June 17, 2022.
American Medical Women’s Association. Patrice A. Harris, MD, MA, n.d.; <https://www.amwa-doc.org/amwa105/patrice-a-harris-md-ma/>; accessed: November 30, 2022.
American Postal Workers Union. Black women raise their voices in the tobacco industry, February 28, 2014; <https://apwu.org/news/black-women-raise-their-voices-tobacco-industry>; accessed: August 24, 2022.
American Indian Religious Freedom Act of 1978, Public Law 95–341, U.S. Statutes at Large 92 (1978):469, codified at U.S. Code 42 (1978):1996.
American Indian Religious Freedom Act Amendments of 1994, Public Law 103–344, U.S. Statutes at Large 108 (1994):3125.
Asian & Pacific Islander American Health Forum. Ethnic-Specific Tobacco Education Network [grant proposal], October 18, 1994; <http://oac-upstream.cdlib.org/ark:/13030/hb7t1nb5bs/?order=2&brand=oac4>; accessed: February 26, 2021.
Asian and Pacific Islander Tobacco Education Network. Asian/Pacific Islander Tobacco Education Network Statewide Conference Report. Paper presented at APITEN Statewide Conference; May 20, 1991.
Asian and Pacific Islander Tobacco Education Network. Case Study: APITEN Advocacy Campaigns in Four Regions of California, 2004; <https://www.apiahf.org/wp-content/uploads/2011/02/CD_Report05_2004-1.pdf>; accessed: May 20, 2020.
Associated Press. Rev. Calvin Butts, influential pillar of Harlem, dies at 73, October 28, 2022; <https://nypost.com/2022/10/28/rev-calvin-butts-influential-pillar-of-harlem-dies-at-73/>; accessed: February 23, 2024.
Brandt AM. Recruiting women smokers: the engineering of consent. Journal of the American Medical Women’s Association (1972) 1996;51(1–2):63–6.
Brennan Ramirez LK, Baker EA, Metzler M. Promoting Health Equity: A Resource to Help Communities Address Social Determinants of Health. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, 2008.
Brnovich M. R. J. Reynolds agrees to stop selling flavored cigarettes [press release], October 11, 2006; <https://www.azag.gov/press-release/r-j-reynolds-agrees-stop-selling-flavored-cigarettes>; accessed: February 19, 2019.
Brown & Williamson. Acoma Pueblo vs. the American Tobacco Company Memorandum Opinion and Order. August 6, 2004. Brown & Williamson Records Collection; Master Settlement Agreement Collection. Bates No. 280945647-280945655. <https://www.industrydocuments.ucsf.edu/docs/hjjb0231>.
Buchting FO, Fagan P, Pien M, Rose A. Lesbians, Gays, Bisexuals, and Transgenders of Color Sampling Methodology: Strategies for Collecting Data in Small, Hidden, or Hard-to-Reach Groups to Reduce Tobacco-Related Health Disparities, 2009; <https://williamsinstitute.law.ucla.edu/wp-content/uploads/LGBT-POC-Sample-Method-Dec-2009.pdf>; accessed: February 19, 2019.
Caffee, Caffee & Associates Public Health Foundation. Executive director, n.d.; <http://ccaphf.org/executive-director>; accessed: November 17, 2022.
California Department of Public Health. California Tobacco Control Branch: media campaign information, May 8, 2017; <https://www.cdph.ca.gov/Programs/CCDPHP/DCDIC/CTCB/Pages/MediaCampaignInformation.aspx>; accessed: March 9, 2021.
Campaign for Tobacco-Free Kids. Deadly Alliance: How Big Tobacco and Convenience Stores Partner to Market Tobacco Products and Fight Life-Saving Policies, 2012; <https://www.tobaccofreekids.org/assets/content/what_we_do/industry_watch/store_report/deadlyalliance_full_report.pdf>; accessed: February 19, 2019.
Campaign for Tobacco-Free Kids. States & Localities That Have Restricted the Sale of Flavored Tobacco Products, 2023; <https://www.tobaccofreekids.org/assets/factsheets/0398.pdf>; accessed: July 27, 2023.
Center for the Study of Tobacco and Society. Dr. Alan Blum, n.d.a; <https://csts.ua.edu/our-team/blum/>; accessed: November 17, 2022.
Center for the Study of Tobacco and Society. Of mice & menthol: the targeting of African Americans by the tobacco industry—activists and advocates, n.d.-b; <https://csts.ua.edu/minorities/minorities-tobacco-big-tobacco-supports-and-suppresses-the-minority-community/anti-smoking-activists-within-african-american-communities/>; accessed: November 17, 2022.
Center for Tobacco Products. Tobacco Products Scientific Advisory Committee (TPSAC) [agenda]. Silver Spring (MD): U.S. Food and Drug Administration, 2011.
Centers for Disease and Control Prevention. CDC-RFA-DP-23-0019: building capacity to reduce the burden of menthol and other flavored commercial tobacco products in communities that experience health disparities, [Notice of Funding Opportunity], 2023; <https://www.cdc.gov/tobacco/about/foa/reduce-burden-menthol/index.html>; accessed: October 13, 2023.
Centers for Disease Control and Prevention. Best Practices User Guide: Health Equity in Tobacco Prevention and Control. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2015a.
Centers for Disease Control and Prevention. National Center for Health Statistics: Healthy People 2010, November 6, 2015b; <https://www.cdc.gov/nchs/healthy_people/hp2010.htm>; accessed: March 9, 2021.
Centers for Disease Control and Prevention. Tips from Former Smokers: about the campaign, 2018; <https://www.cdc.gov/tobacco/campaign/tips/about/index.html>; accessed: February 19, 2019.
Centers for Disease Control and Prevention. Media statement from CDC Director Rochelle P. Walensky, MD, MPH, on racism and health, April 8, 2021; <https://www.cdc.gov/media/releases/2021/s0408-racism-health.html>; accessed: July 25, 2022.
Centers for Disease Control and Prevention. Attaining health equity, n.d.; <https://www.cdc.gov/nccdphp/dch/programs/healthycommunitiesprogram/overview/healthequity.htm>; accessed: April 14, 2022.
Chicago Tribune. The Rev. Michael Pfleger, activist pastor, April 4, 2012; <https://www.chicagotribune.com/news/chi-080611-father-pfleger-photogallery-photogallery.html>; accessed: November 17, 2022.
City and County of San Francisco. June 5, 2018 election results—summary, 2018; <https://sfelections.sfgov.org/june-5-2018-election-results-summary>; accessed: February 19, 2019.
Clayton RR. The Tobacco Research Network on Disparities (TReND). Journal of Epidemiology and Community Health 2006;60(Suppl 2):3–4.
Cornell Law School. Sharon Eubanks, n.d.; <https://lawyers.law.cornell.edu/lawyer/sharon-eubanks-592115>; accessed: November 17, 2022.
Crenshaw K. Mapping the margins: intersectionality, identity politics, and violence against women of color. Stanford Law Review 1991;43(6):1241–99.
D’Silva J, O’Gara E, Villaluz NT. Tobacco industry misappropriation of American Indian culture and traditional tobacco. Tobacco Control 2018;27(e1):e57–e64.29459389
Delta Sigma Theta Sorority, Inc. Proposed resolutions, 2017; <https://www.deltasigmatheta.org/wp-content/uploads/2021/05/Resolutions-for-Consideration-Final.pdf>; accessed: June 30, 2022.
Devex. National African American Tobacco Prevention Network (NAATPN), n.d.; <https://www.devex.com/organizations/national-african-american-tobacco-prevention-network-naatpn-121872>; accessed: December 5, 2022.
Encyclopedia Virginia. Worker strike at R.J. Reynolds Tobacco Company, 1947; <https://encyclopediavirginia.org/8432-3dc823cd536e3fe/>; accessed: August 24, 2022.
Encyclopedia.com. Abyssinian Baptist Church, n.d.; <https://www.encyclopedia.com/history/encyclopedias-almanacs-transcripts-and-maps/abyssinian-baptist-church>; accessed: February 23, 2024.
Ernster VL. Mixed messages for women. A social history of cigarette smoking and advertising. New York State Journal of Medicine 1985;85(7):335–40.3900827
Fagan P, King G, Lawrence D, Petrucci SA, Robinson RG, Banks D, Marable S, Grana R. Eliminating tobacco-related health disparities: directions for future research. American Journal of Public Health 2004;94(2):211–7.14759929
Federal Register. Executive Office of the President. Advancing Racial Equity and Support for Under-served Communities Through the Federal Government (Executive Order 13985), 86 Fed. Reg. 7009 (2021).
Federal Register. Executive Office of the President. Further advancing racial equity and support for underserved communities through the federal government (Executive Order 14091), 88 Fed. Reg. 10825 (2023).
Federal Register. Executive Office of the President, Office of Management and Budget, Office of Information and Regulatory Affairs. Revisions to the standards for the classification of federal data on race and ethnicity, 62 Fed. Reg. 210 (1997a).
Federal Register. Centers for Disease Control and Prevention. Initiatives by organizations to strengthen national tobacco control activities in the United States (Announcement 763), 62 Fed. Reg. 36550 (1997b).
Federal Register. U.S. Department of Health and Human Services, Food and Drug Administration. Menthol in cigarettes, tobacco products; request for comments (21 CFR Part 1140), 78 Fed. Reg. 44484 (2013).
Federal Register. U.S. Department of Health and Human Services, Food and Drug Administration. Tobacco product standard for menthol in cigarettes, proposed rule (21 CFR 1162), 87 Fed. Reg. 26454 (2022a).
Federal Register. U.S. Department of Health and Human Services, Food and Drug Administration. Deeming tobacco products to be subject to the Federal Food, Drug, and Cosmetic Act, as amended by the Family Smoking Prevention and Tobacco Control Act; restrictions on the sale and distribution of tobacco products and required warning statements for tobacco products, 81 Fed. Reg. 28973 (2016a); <https://www.federalregister.gov/d/2016-10685>; accessed: February 19, 2019.
Federal Register. U.S. Department of Housing and Urban Development, Office of the Assistant Secretary for Public and Indian Housing. Instituting smoke-free public housing: a proposed rule by the Housing and Urban Development Department on 11/17/2015, 80 Fed. Reg. 87430 (2016b); <https://www.federalregister.gov/d/2016-28986>; accessed: February 19, 2019.
Federal Register. U.S. Food and Drug Administration. Regulation of flavors in tobacco products, 83 Fed. Reg. 12294 (2018).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Definition of the term “tobacco product” in regulations issued under the Federal Food, Drug, and Cosmetic Act, 88 Fed. Reg. 1655 (2023).
Federal Register. U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Tobacco product standard for characterizing flavors in cigars; proposed rule (21 CFR Part 1166), 87 Fed. Reg. 26396 (2022b).
Fernander AF. Racially classified social group tobacco-related health disparities: what is the role of genetics? Addiction 2007;102(Suppl 2):58–64.17850614
Flanagin A, Frey T, Christiansen SL, AMA Manual of Style Committee. Updated guidance on the reporting of race and ethnicity in medical and science journals. JAMA: the Journal of the American Medical Association 2021;326(7):621–7.34402850
Fortune Magazine. Spuds. February 1932. Philip Morris Records Collection. Bates No. 075957573-2075957578. <https://www.industrydocuments.ucsf.edu/docs/txff0104>.
Freeman HP. Center to Reduce Cancer Health Disparities. Presentation at the 126th Meeting of the National Cancer Advisory Board, National Cancer Institute; June 10, 2003; Bethesda (MD).
Freiberg M. The minty taste of death: state and local options to regulate menthol in tobacco products. Catholic University Law Review 2015;64(4):949–74.
Gardiner PS. The African Americanization of menthol cigarette use in the United States. Nicotine & Tobacco Research 2004;6(Suppl 1):S55–S65.14982709
Greaves L, Vallone D, Velicer W. Special effects: tobacco policies and low socioeconomic status girls and women. Journal of Epidemiology and Community Health 2006;60(Suppl 2):1–2.17708002
Hafez N, Ling PM. Finding the Kool Mixx: how Brown & Williamson used music marketing to sell cigarettes. Tobacco Control 2006;15(5):359–66.16998169
Hammond EC, Horn D. The relationship between human smoking habits and death rates: a follow-up study of 187,766 men. JAMA: the Journal of the American Medical Association 1954;155(15):1316–28.
Healton CG, Haviland ML, Vargyas E. Will the master settlement agreement achieve a lasting legacy? Health Promotion Practice 2004;5(3 Suppl):12S–17S.15231091
Heise K. Henry McNeil Brown, 61, activist, September 28, 1996; <https://www.chicagotribune.com/news/ct-xpm-1996-09-28-9609280109-story.html>; accessed: November 17, 2022.
Hurt RD, Ebbert JO, Muggli ME, Lockhart NJ, Robertson CR. Open doorway to truth: legacy of the Minnesota tobacco trial. Mayo Clinic Proceedings 2009;84(5):446–56.19411441
Janiewski DE. Making factories without walls. In: Sisterhood Denied: Race, Gender, and Class in a New South Community. Philadelphia (PA): Temple University Press, 1985:8–26.
Keep It Sacred. Traditional tobacco, n.d.; <https://keepitsacred.itcmi.org/tobacco-and-tradition/traditional-tobacco-use/>; accessed: March 2, 2022.
King G. The “race” concept in smoking: a review of the research on African Americans. Social Science & Medicine 1997;45(7):1075–87.9257399
Kuiper N, Zhang L, Lee J, Babb SD, Anderson CM, Shannon C, Welton M, Lew R, Zhu SH. A national Asian-language smokers’ quitline—United States, 2012–2014. Preventing Chronic Disease 2015;12:E99.26111159
Legal Information Institute. Preemption, n.d.; <https://www.law.cornell.edu/wex/preemption>; accessed: February 23, 2024.
Maine Legislature. Title 22: Health and welfare. Subtitle 2: health. Part 3: public health. Chapter 262-A: retail tobacco sales. Subchapter 5: flavored cigars (Maine Revised Statutes §1560-D), 2007; <http://www.mainelegislature.org/legis/statutes/22/title22sec1560-D.html>; accessed: February 19, 2019.
Maine Legislature. An Act to Make Maine’s Laws Consistent with the Federal Family Smoking Prevention and Tobacco Control Act (Maine Revised Statutes §1560-D), 2010; <https://www.mainelegislature.org/legis/bills/bills_124th/chappdfs/PUBLIC606.pdf>; accessed: March 13, 2023.
McCandless PM, Yerger VB, Malone RE. Quid pro quo: tobacco companies and the Black press. American Journal of Public Health 2012;102(4):739–50.21852652
McClory R. Victory and beyond. In: Radical Disciple: Father Pfleger, St. Sabina Church and the Fight for Social Justice. Chicago (IL): Lawrence Hill Books, 2010:76–156.
McLellan DL, Kaufman NJ. Examining the effects of tobacco control policy on low socioeconomic status women and girls: an initiative of the Tobacco Research Network on Disparities (TReND). Journal of Epidemiology and Community Health 2006;60(Suppl 2):5–6.
Merriam-Webster. Racialize, n.d.; <http://www.merriam-webster.com/dictionary/racialize>; accessed: June 7, 2022.
Michigan House Democrats. Biography for Rep. Tinsley Talabi, n.d.; <https://web.archive.org/web/20150530120637/http://www.housedems.com/state-rep-alberta-tinsley-talabi-biography>; accessed: February 23, 2024.
Minority Health and Health Disparities Research and Education Act of 2000, Public Law 106–525, U.S. Statutes at Large 114 (2000):2495.
Muhammed JG. Tobacco giant hit again for targeting minors, November 29, 2006; <https://new.finalcall.com/2006/11/29/tobacco-giant-hit-again-for-targeting-minors/>; accessed: November 17, 2022.
National African American Tobacco Prevention Network. About, n.d.; <https://naatpn.wordpress.com/about/>; accessed: February 23, 2024.
National Archives. Milestone documents: Dawes Act (1887), n.d.; <https://www.archives.gov/milestone-documents/dawes-act>; accessed: November 14, 2022.
National Association for the Advancement of Colored People. Support state and local restrictions on the sale of flavored tobacco products, n.d.; <https://naacp.org/resources/support-state-and-local-restrictions-sale-flavored-tobacco-products>; accessed: August 5, 2022.
National Association of African Americans for Positive Imagery. African American activists seek end to menthol cigarettes in civil rights lawsuit against tobacco companies [news release], October 21, 1998; <http://www.tcsg.org/tobacco/minorities/mentholpr.htm>; accessed: March 6, 2024.
National Association of African Americans for Positive Imagery. Fact sheet: menthol civil rights lawsuit, May 18, 2001; <http://www.naaapi.org/documents/civil_suit_factsht.asp>; accessed: March 9, 2021.^*^
National Cancer Institute. Annotated Bibliography of Cancer-Related Literature on Black Populations. Bethesda (MD): U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Cancer Institute, 1988. NIH Publication No. 89-3024.
National Cancer Institute. A Socioecological Approach to Addressing Tobacco-Related Health Disparities. Tobacco Control Monograph 22. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2017. NIH Publication No. 17-CA-8035A.
National Cancer Institute. Strategies to Control Tobacco Use in the United States: A Blueprint for Public Health Action in the 1990s. Smoking and Tobacco Control Monograph No. 1. Bethesda (MD): U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Cancer Institute, 1991. NIH Publication No. 92-3316.
National Cancer Institute. Guía: Viva de Forma más Saludable Para Usted y su Familia [Spanish], October 2011; <https://smokefree.gov/sites/default/files/pdf/guia-para-dejar-de-fuma-2011.pdf>; accessed: December 5, 2022.
National Cancer Institute. TReND: Low SES women and girls project: examining the effects and potential unintended consequences of tobacco control policies on low SES women and girls, 2012; <https://cancercontrol.cancer.gov/brp/archive/trend/low_ses_women.html#about>; accessed: February 19, 2019.
National Cancer Institute. A Socioecological Approach to Addressing Tobacco-Related Health Disparities. Tobacco Control Monograph 22. Bethesda (MD): U.S. Department of Health and Human Services, National Institutes of Health, National Cancer Institute, 2017. NIH Publication No. 17-CA-8035A.
National Cancer Institute. TUS-CPS translations into other languages, 2022a; <https://cancercontrol.cancer.gov/brp/tcrb/tus-cps/language-translations>; accessed: August 5, 2022.
National Cancer Institute. What topics do the TUS-CPS questionnaires cover?, February 24, 2022b; <https://cancercontrol.cancer.gov/brp/tcrb/tus-cps/survey-topics>; accessed: June 30, 2022.^*^
National Center for Health Statistics. National Health Interview Survey: sexual orientation information background, n.d.; <https://www.cdc.gov/nchs/nhis/sexual_orientation/background.htm>; accessed: June 30, 2022.
National Center on Minority Health and Health Disparities. About NIMHD, n.d.; <https://www.nimhd.nih.gov/about/>; accessed: February 26, 2021.
National Geographic. Native Americans and freedom of religion, n.d.; <https://education.nationalgeographic.org/resource/native-americans-and-freedom-religion/> accessed: June 17, 2022.
National Institute on Minority Health and Health Disparities. History, n.d.; <https://www.nimhd.nih.gov/about/overview/history/>; accessed: May 17, 2023.
National Institutes of Health. NIH Style Guide: Race and national origin, 2024; <https://www.nih.gov/nih-style-guide/race-national-origin>; accessed: February 22, 2024.
National Jewish Health. National Jewish Health launches commercial tobacco program customized for American Indians: First of its kind QuitLogix Tobacco-Cessation Program designed specifically to help underserved population [press release], July 29 2015; <https://www.nationaljewish.org/about/news/press-releases/2015/njh-launches-tobacco-program-for-american-indians>; accessed: February 19, 2019.
National Latino Council on Alcohol and Tobacco Prevention. Take Action; Create Change, A Community Organizing Toolkit, n.d.; <https://cdn.ymaws.com/www.wpha.org/resource/resmgr/health_&_racial_equity/lcat_take_action_create_chan.pdf>; accessed: August 5, 2022.
National LGBT Cancer Network. About us: Scout, MA PhD, Executive Director, n.d.; <https://cancer-network.org/about/people/scout-ma-phd/>; accessed: June 14, 2023.
Native Voices. 1953: Congress seeks to abolish tribes, relocate American Indians, 1953; <https://www.nlm.nih.gov/nativevoices/timeline/488.html>; accessed: August 3, 2022.
Navajo-Hopi Observer. Dr. Patricia Nez Henderson elected president of Society for Research on Nicotine and Tobacco, March 10, 2022; <https://www.nhonews.com/news/2022/mar/10/dr-patricia-nez-henderson-elected-president-societ/>; accessed: December 5, 2022.
Nelson MD. Re: Docket No. FDA-2013-P-0435 [Letter: FDA response to citizen-signed petition regarding menthol], April 29, 2021; <https://downloads.regulations.gov/FDA-2013-P-0435-0106/attachment_1.pdf>; accessed: August 5, 2022.
New York State Attorney General. Landmark settlement of “Kool Mixx” tobacco lawsuits [press release], October 6, 2004; <https://ag.ny.gov/press-release/2004/landmark-settlement-kool-mixx-tobacco-lawsuits>; accessed: February 15, 2019.
New York Times. California election results, November 30, 2022; <https://www.nytimes.com/interactive/2022/11/08/us/elections/results-california-proposition-31-flavored-tobacco-ban-referendum.html>; accessed: November 30, 2022.
Newberry RC. Reynolds right to drop Black-aimed cigarette test, January 24, 1990; <https://csts.ua.edu/files/2019/09/1990-01-24-The-Houston-Post-Robert-Newberry-Reynolds-right-to-drop-black-aimed-cigarette-test.pdf>; accessed: November 17, 2022.
Nez Henderson P, Lee JP, Soto C, O’Leary R, Rutan E, D’Silva J, Waa A, Henderson ZP, Nez SS, Maddox R. Decolonization of tobacco in indigenous communities of Turtle Island (North America). Nicotine & Tobacco Research 2022;24(2):289–91.34516637
Nicotine & Tobacco Research. Supplement 1: menthol cigarettes—setting the research agenda. Nicotine & Tobacco Research 2004:6.
Nicotine & Tobacco Research. Menthol cigarettes: moving toward a broader definition of harm. Nicotine & Tobacco Research 2010;12(Suppl 2).
North American Quitline Consortium. American Indian Quitline program for Minnesota residents [press release], May 14, 2018; <https://www.naquitline.org/news/400861/American-Indian-Quitline-Program-for-Minnesota-Residents.htm>; accessed: February 19, 2019.
North American Quitline Consortium. Rod Lew to receive the APHA ATOD Andre Stanley Memorial Health Equity Award, November 20, 2019; <https://www.naquitline.org/news/478917/Rod-Lew-to-Receive-the-APHA-ATOD-Andre-Stanley-Memorial-Health-Equity-Award.htm>; accessed: December 5, 2022.
North American Quitline Consortium. [Biography on Jeannette Noltenius], n.d.; <https://cdn.ymaws.com/www.naquitline.org/resource/resmgr/bod2011/jnbiofinal.pdf>; accessed: November 17, 2022.
Oakland City Council. Ordinance no. 13452 C.M.S.: Ordinance amending Oakland Municipal Code chapter 5.91 to: (1) prohibit the sale of flavored tobacco products; (2) require the posting of the full retail price of tobacco products; (3) prohibit the redemption of tobacco discounts and coupons; and (4) make administrative changes for the licensure of tobacco retailers, July 20, 2017; <https://library.municode.com/ca/oakland/ordinances/code_of_ordinances?nodeId=854090>; accessed: April 20, 2020.
Office of Disease Prevention and Health Promotion. Healthy People 2020: disparities, n.d.; <https://wayback.archive-it.org/5774/20220414003754/https://www.healthypeople.gov/2020/about/foundation-health-measures/Disparities>; accessed: February 23, 2024.
Office of Disease Prevention and Health Promotion. History of Healthy People, 2021; <https://health.gov/our-work/national-health-initiatives/healthy-people/about-healthy-people/history-healthy-people>; accessed: February 23, 2024.
Okuyemi KS, Reitzel LR, Fagan P. Interventions to reduce tobacco-related health disparities. Nicotine & Tobacco Research 2015;17(8):887–91.26180213
Parker SG. Introducing a Latino voice into the debate on substance abuse treatment, 2003; <https://www.rwjf.org/en/library/research/2003/02/introducing-a-latinovoice-into-the-debate-on-substance-abuse-tr.html>; accessed: November 17, 2022.^*^
Patient Protection and Affordable Care Act, Public Law 111–148, U.S. Statutes at Large 110 (2010).
Powers M, Faden R. Social Justice: The Moral Foundations of Public Health and Health Policy. New York (NY): Oxford University Press, 2006.
Public Health Law Center. Settlement agreement and stipulation for entry of consent judgment, State of Minnesota et al. v. Philip Morris, et al, 1998; <https://publichealthlawcenter.org/sites/default/files/resources/mn-settlement-agreement.pdf>; accessed: June 28, 2022.
Public Health Law Center. The Master Settlement Agreement: An Overview, 2019; <https://www.publichealthlawcenter.org/sites/default/files/resources/MSA-Overview-2019.pdf>; accessed: March 9, 2020.
Public Health Law Center. FDA menthol timeline, n.d.a; <https://publichealthlawcenter.org/resources/fda-menthol-timeline>; accessed: June 30, 2022.
Public Health Law Center. Lorillard v. FDA (2011), n.d.b; <https://www.publichealthlawcenter.org/litigation-tracker/lorillard-v-fda-2011>; accessed: February 23, 2024.
Public Health Law Center. R.J. Reynolds Tobacco v. U.S. Food & Drug Administration, n.d.c; <http://www.publichealthlawcenter.org/content/us-v-philip-morris-usa-inc>; accessed: February 19, 2019.
Public Health Law Center. R.J. Reynolds v. Bonta (2022), n.d.d; <https://www.publichealthlawcenter.org/litigation-tracker/rj-reynolds-v-bonta-2022>; accessed: February 23, 2024.
Public Health Law Center. U.S. v. Philip Morris USA, Inc., n.d.e; <http://www.publichealthlawcenter.org/content/us-v-philip-morris-usa-inc>; accessed: February 19, 2019.
Ramirez A. A cigarette campaign under fire. The New York Times, February 19, 1990a; <https://www.nytimes.com/1990/01/12/business/a-cigarette-campaign-under-fire.html>; accessed: February 15, 2019.
Ramirez A. Reynolds, after protests, cancels cigarette aimed at Black smokers. The New York Times, 1990b; <https://www.nytimes.com/1990/01/20/us/reynolds-after-protests-cancels-cigarette-aimed-at-black-smokers.html>; accessed: February 15, 2019.
Robinson RG, Sutton CD, James DA, Orleans CT. Pathways to Freedom: Winning the Fight Against Tobacco. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, 2006.
Robles F. Jury awards $23.6 billion in Florida smoking case. The New York Times, 2014; <https://www.nytimes.com/2014/07/20/business/jury-awards-23-6-billion-in-florida-smoking-case.html>; accessed: February 19, 2019.
Roeseler A, Burns D. The quarter that changed the world. Tobacco Control 2010;19(Suppl 1):i3–i15.20382647
Rothe EM, Tzuang D, Pumariega AJ. Acculturation, development, and adaptation. Child and Adolescent Psychiatric Clinics of North America 2010;19(4):681–96.21056341
Smokefree Casinos. Navajo Nation is saving countless lives by protecting its people from secondhand smoke, November 8, 2021; <https://smokefreecasinos.org/navajo-nation-president-signs-bill-to-make-its-4-casinos-smokefree/>; accessed: November 17, 2022.
Society for Research on Nicotine & Tobacco. 2022 President’s Award, n.d.; <https://www.srnt.org/page/2022_Presidents_award#:~:text=Dr.%20Pebbles%20Fagan%20will%20receive%20the%202022%20SRNT,health%20inequities%20related%20to%20nicotine%20and%20tobacco%20use>; accessed: December 4, 2022.
Stanford Research into the Impact of Tobacco Advertising. Racist [search results], 2022; <https://tobacco.stanford.edu/search-results/?_sf_s=racist>; accessed: August 24, 2022.
Substance Abuse and Mental Health Services Administration. 2019 National Survey on Drug Use and Health (NSDUH): Methodological Summary and Definitions—NSDUH Methodological Report, September 2020; <https://www.samhsa.gov/data/report/2019-methodological-summary-and-definitions>; accessed: February 7, 2024.
Sutton CD. The Coalition Against Uptown Cigarettes: marketing practices and community mobilization (unpublished report). In: Mallyroyal, Musings From My Mom: The Coalition Against Uptown Cigarettes, August 26, 2013; <https://www.dailykos.com/stories/2013/8/26/1233917/-Musings-From-My-Mom-The-Coalition-Against-Uptown-Cigarettes>; accessed: February 23, 2024.
Swan R. SF’s battle over flavored tobacco heats up. San Francisco Chronicle, September 4, 2017.
Tadayon A. Oakland bans flavored tobacco products. East Bay Times, 2017; <https://www.eastbaytimes.com/2017/09/20/oakland-bans-flavored-tobacco-products/>; accessed: February 19, 2019.
Tadayon A. Richmond bans menthol, other flavored tobacco. East Bay Times, July 19, 2018; <https://www.eastbaytimes.com/2018/07/19/richmond-bans-menthol-other-flavored-tobacco/>; accessed: March 19, 2020.
Tangari AH, Kees J, Andrews JC, Burton S. Can corrective ad statements based on U.S. v. Philip Morris U.S.A. Inc. affect consumer beliefs about smoking? Journal of Public Policy and Marketing 2010;29(2):153–69.
The George Washington University, Milken Institute School of Public Health. Equity vs. equality: what’s the difference?, November 5, 2020; <https://onlinepublichealth.gwu.edu/resources/equity-vs-equality>; accessed: March 3, 3022.
The National Trial Lawyers. $23 billion tobacco verdict reduced to $16.9 million, n.d.; <https://thenationaltriallawyers.org/article/23b-engle-verdict/>; accessed: May 17, 2023.
The New York Times. Text of letter to senators on menthol exemption for cigarettes, The New York Times, June 5, 2008; <https://www.nytimes.com/2008/06/05/business/05TobaccoLetter.html>; accessed: February 19, 2019.
Themba-Nixon M, Sutton CD, Shorty L, Lew R, BaezcondeGarbanati L. More money more motivation? Master Settlement Agreement and tobacco control funding in communities of color. Health Promotion Practice 2004;5(3 Suppl):113S–128S.15231105
Tobacco Control Legal Consortium. Federal Regulation of Tobacco: A Summary. St. Paul (MN): Tobacco Control Legal Consortium, July 2009.
Tobacco Control Legal Consortium. Citizen Petition: Asking the U.S. Food and Drug Administration to Prohibit Menthol as a Characterizing Flavor in Cigarettes, April 12, 2013; <https://www.publichealthlawcenter.org/sites/default/files/resources/tclc-fdacitizenpetition-menthol-2013.pdf>; accessed: February 19, 2019.
Tobacco Control Legal Consortium. Chicago’s Regulation of Menthol Flavored Tobacco Products: A Case Study. St. Paul (MN): Public Health Law Center at Mitchell Hamline School of Law, 2016.
Tobacco Control Legal Consortium. How the Affordable Care Act Affects Tobacco Use and Control, n.d.; <https://publichealthlawcenter.org/sites/default/files/tclc-fs-aca-&-tobacco-control-2014_0.pdf>; accessed: February 19, 2019.
Tobacco Products Scientific Advisory Committee. Menthol Cigarettes and Public Health: Review of the Scientific Evidence and Recommendations. Washington (DC): U.S. Food and Drug Administration, 2011.
Tobacco Tactics. Racism and the tobacco industry, February 10, 2021; <https://tobaccotactics.org/wiki/racism-and-the-tobacco-industry/>; accessed: August 24, 2022.
Tong EK, Fagan P, Cooper L, Canto M, Carroll W, Foster-Bey J, Hebert JR, Lopez-Class M, Ma GX, Nez Henderson P, . Working to eliminate cancer health disparities from tobacco: a review of the National Cancer Institute’s Community Networks Program. Nicotine & Tobacco Research 2015;17(8):908–23.26180215
Trinkets & Trash. Spud menthol cooled cigarettes, cork tip, n.d.; <https://trinketsandtrash.org/detail.php?artifactid=3067>; accessed: November 16, 2022.
Truth Initiative. Three key moments in the history of marketing tobacco to women, August 26, 2016a; <https://truthinitiative.org/research-resources/tobacco-industry-marketing/three-key-moments-history-marketing-tobacco-women>; accessed: August 24, 2022.
Truth Initiative. Where we stand: regulating flavored tobacco products, August 23, 2016b; <https://truthinitiative.org/research-resources/tobacco-prevention-efforts/where-we-stand-regulating-flavored-tobacco-products>; accessed: June 30, 2022.
Truth Initiative. Tobacco Nation: An Ongoing Crisis—Examining the Health and Policy Disparities of U.S. States with the Highest Smoking Rates, June 2019; <https://truthinitiative.org/sites/default/files/media/files/2019/06/Tobacco-Nation-An-Ongoing-Crisis.pdf>; accessed: July 26, 2022.
U.S. Department of Health, Education, and Welfare. Smoking and Health: Report of the Advisory Committee to the Surgeon General of the Public Health Service. Washington (DC): U.S. Department of Health, Education, and Welfare, Public Health Service, Center for Disease Control, 1964. PHS Publication No. 1103.
U.S. Department of Health and Human Services. The Health Consequences of Smoking: Cancer and Chronic Lung Disease in the Workplace. A Report of the Surgeon General. Rockville (MD): U.S. Department of Health and Human Services, Public Health Service, Office on Smoking and Health, 1985. DHHS Publication No. (PHS) 85-50207.
U.S. Department of Health and Human Services. Tobacco Use Among U.S. Racial/Ethnic Minority Groups—African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1998.
U.S. Department of Health and Human Services. Reducing Tobacco Use. A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2000.
U.S. Department of Health and Human Services. Women and Smoking. A Report of the Surgeon General. Rockville (MD): U.S. Department of Health and Human Services, Public Health Service, Office of the Surgeon General, 2001.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2012.
U.S. Department of Health and Human Services. The Health Consequences of Smoking—50 Years of Progress: A Report of the Surgeon General. Atlanta (GA): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 2014.
U.S. Department of Housing and Urban Development, Office of the Assistant Secretary for Public and Indian Housing. Instituting smoke-free public housing; final rule (924 CFR Parts 965 and 966), Docket No. FR 5597-F-03, RIN 2577-AC97, 2016; <https://www.hud.gov/sites/documents/SMOKEFREEPHFINALRULE.PDF>; accessed: June 30, 2022.
U.S. Food and Drug Administration. Fresh Empire campaign, 2022a; <https://www.fda.gov/tobacco-products/public-health-education-campaigns/fresh-empire-campaign>; March 6, 2024.
U.S. Food and Drug Administration. Real Cost campaign, 2019; <https://www.fda.gov/TobaccoProducts/PublicHealthEducation/PublicEducationCampaigns/TheRealCostCampaign/default.htm>; accessed: February 19, 2019.
U.S. Food and Drug Administration. Family Smoking Prevention and Tobacco Control Act—an overview, June 3, 2020; <https://www.fda.gov/tobacco-products/rules-regulations-and-guidance/family-smoking-prevention-and-tobacco-control-act-overview>; accessed: February 23, 2024.
U.S. Food and Drug Administration. This Free Life campaign, March 11, 2022b; <https://www.fda.gov/TobaccoProducts/PublicHealthEducation/PublicEducationCampaigns/ThisFreeLifeCampaign/default.htm>; accessed: August 22, 2023.
U.S. Food and Drug Administration. Preliminary Scientific Evaluation of the Possible Public Health Effects of Menthol Versus Nonmenthol Cigarettes, n.d.; <https://www.fda.gov/media/86497/download>; accessed: March 1, 2024.
Unger JB, Soto C, Baezconde-Garbanati L. Perceptions of ceremonial and nonceremonial uses of tobacco by American-Indian adolescents in California. Journal of Adolescent Health 2006;38(4):443.e9–443.e16.
United States v. Philip Morris USA Inc., 449 F. Supp. 2d 1 (2006), aff’d in relevant part, 566 F.3d 1095 (D.C. Cir. 2009).
University of California. Tobacco-Related Disease Research Program: Annual Report 2003, 2003; <http://www.trdrp.org/files/annual-report/Annualreport2003.pdf>; accessed: February 19, 2019.
University of Illinois Chicago School of Public Health. SPH announces André Gilmore Stanley DrPH Scholarship in Equity and Anti-Racism, October 13, 2021; <https://publichealth.uic.edu/news-stories/sph-announces-andre-gilmore-stanley-drph-scholarship-in-equity-and-anti-racism/>; accessed: November 17, 2022.
University of North Carolina at Chapel Hill Program for Ethnicity, Culture, and Health Outcomes. Minority Health Project to eliminate health disparities: announcements 2005–2006, n.d.; <http://www.epidemiolog.net/mhp/announce/pastannounce/2006.cfm.html>; accessed: August 5, 2022.
University of Southern California. Latino conference honors USC tobacco prevention expert, March 1, 2002; <https://news.usc.edu/3534/Latino-conference-honorsUSC-tobacco-prevention-expert/>; accessed: December 5, 2022.^*^
Whitehead M, Dahlgren G. Levelling Up (Part 1): A Discussion Paper on Concepts and Principles for Tackling Social Inequities in Health. Copenhagen (Denmark): World Health Organization, Regional Office for Europe, 2006.
World Health Organization. Gender and health, n.d.; <https://www.who.int/health-topics/gender#tab=tab_1>; accessed: March 3, 2022.
Yerger VB, Malone RE. African American leadership groups: smoking with the enemy. Tobacco Control 2002;11(4):336–45.12432159

1 More recently, CDC (2022a) has recommended avoiding using the term vulnerable, noting that it implies an inherent condition rather than causal factors.

2 Established by the federal government in the 1920s and 1930s, redlining was a discriminatory housing policy that discouraged banks from offering mortgages in neighborhoods that had a high percentage of residents from certain racial and ethnic groups (U.S. Department of Justice 2021; Legal Information Institute n.d.).

3 The Tobacco Control Act (2009) expressly preempts state, territorial, and local requirements that differ from, or add to, any FDA requirements related to “tobacco product standards, premarket review, adulteration, misbranding, labeling, registration, good manufacturing standards, or modified risk tobacco products” (p. 1823), but the Act also clarifies that there is no preemption of any other measures. The Tobacco Control Act does not have relevance to state preemption of local action. See Chapter 7 for further discussion about preemption.

* URL was active on the access date shown in the reference entry but was no longer active when this Surgeon General’s report was released.