# List of Abbreviations

μg/m^3^: micrograms per cubic meter of air
µM: micromolar
AAC: Ask, Advise, Connect
AAPC: average annual percent change
AAR: Ask, Advise, Refer
ACA: Patient Protection and Affordable Care Act
ACHA: American College Health Association
ACO: accountable care organization
Add Health: National Longitudinal Study of Adolescent to Adult Health
ADI: acceptable daily intake
AIMS: Abnormal Involuntary Movements Scale
ANBL: All Nations Breath of Life
ANPRM: Advanced Notice of Proposed Rulemaking
AoA: Administration on Aging
aOR: adjusted odds ratio
APC: annual percent change
aRR: adjusted relative risk
aRR: adjusted risk ratio
ASQ: Asian Smokers’ Quitline
ATP: adenosine triphosphate
AUDADIS-5: Alcohol Use Disorder and Associated Disabilities Interview Schedule-5
BAM: Behavioral Activation Model
BARS: Barnes Akathisia Rating Scale
BASF: Badische Anilin und Soda Fabrik
BOP: Bureau of Prisons
BPRS: Brief Psychiatric Rating Scale
BRFSS: Behavioral Risk Factor Surveillance System
C3I: Cancer Center Cessation Initiative
cAMP: cyclic adenosine monophosphate
CAS: Chemical Abstract Service
CBPR: community-based participatory research
CBT: cognitive behavioral therapy
CCQ: Clinical COPD Questionnaire
CD: compact disc
CDC: Centers for Disease Control and Prevention
CEMA: N-Acetyl-S-(2-cyanoethyl)-L-cysteine
CES: Cigarette Evaluation Scale
CES-D: Center for Epidemiological Studies-Depression Scale
CI: confidence interval
CISNET: Cancer Intervention and Surveillance Modeling Network
CLD: causal loop diagram
CMS: Centers for Medicare and Medicaid Services
CNA: certified nursing assistant
cNRT: combination nicotine patches and nicotine lozenges
CO: carbon monoxide
ComPASS: Community Partnerships to Advance Science for Society
COPD: chronic obstructive pulmonary disease
CORE: Congress of Racial Equality
CPD: cigarettes smoked per day
CPT: cigarette purchase task
CST: cultural smokeless tobacco
DSM IV: Diagnostic and Statistical Manual of Mental Disorders, 4th edition
DSM-5: Diagnostic and Statistical Manual of Mental Disorders, 5th edition
DTBP: ditert butylphenol
DVD: digital video disk
EAGLES: Evaluating Adverse Events in Global Smoke Cessation Study
e-cigarette: electronic cigarette
ED: emergency department
EHR: electronic health record
ENDS: electronic nicotine delivery systems
FD&C Act: Federal Food, Drug, and Cosmetic Act
FDA: U.S. Food and Drug Administration
FEMA: Flavor and Extract Manufacturers Association
FEV1: forced expiratory volume in 1 second
FQHC: Federally Qualified Health Center
FSFW: Foundation for a Smoke-Free World
FTC: Federal Trade Commission
FTCD: Fagerstrom Test of Cigarette Dependence
FTND: Fagerstrom Test of Nicotine Dependence
g: gram
GED: General Educational Development (certificate or diploma)
GHE: general health education
GPCR: G-protein-coupled receptor
GRAS: generally recognized as safe
GRP: Gross Rating Point
GSSP:GSH: ratio of glutathione to oxidized glutathione
HAVE: Host-Agent-Vector-Environment
HBCUs: Historically Black Colleges and Universities
HDM: high-intensity disease management
HONC: Hooked on Nicotine Checklist
HPHC: harmful and potentially harmful constituent
HRBS: Health-Related Behaviors Survey
HRSA: Health Resources and Services Administration
HUD: U.S. Department of Housing and Urban Development
IARC: International Agency for Research on Cancer
ICD: International Classification of Diseases
IFF: International Flavors & Fragrances
IFRA: International Fragrance Association
IOM: Institute of Medicine
IPFQR: Inpatient Psychiatric Facility Quality Reporting
ITC: International Tobacco Control
IVR: interactive voice response
kg: kilogram
LDC: Libre del Cigarrillo
LGBTQ+: lesbian, gay, bisexual, transgender, queer, or intersex
LMF: linked mortality file
LNC: low-nicotine-content
MAO: monoamine oxidase
MBAT: mindfulness-based addiction treatment
MDM: moderate-intensity disease management
MEC: Mobile Examination Center
mg: milligram
mHealth: mobile health
MI: motivational interviewing
mL: milliliter
MNWS: Minnesota Nicotine Withdrawal Scale
MRGPCR: Mas-related G-protein-coupled receptor
MTF: Monitoring the Future
NAACP: National Association for the Advancement of Colored People
nAChR: nicotinic acetylcholine receptor
NASCAR: National Association for Stock Car Auto Racing
NATS: National Adult Tobacco Survey
NCHS: National Center for Health Statistics
NCI: National Cancer Institute
NDI: National Death Index
NDSS: Nicotine Dependence Syndrome Scale
NESARC-III: National Epidemiologic Survey on Alcohol and Related Conditions III
ng: nanogram
ng/mL: nanograms per milliliter
NHANES: National Health and Nutrition Examination Survey
NHIS: National Health Interview Survey
NICU: neonatal intensive care unit
NIH: National Institutes of Health
NIOSH: National Institute for Occupational Safety and Health
nmol: nanomole
NNAL/Cr: 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanol/creatinine
NNC: normal-nicotine-content
NNPA: National Negro Publishers Association
NRT: nicotine replacement therapy
NSDUH: National Survey on Drug Use and Health
NTS: nucleus tractus solitarius
NYTS: National Youth Tobacco Survey
OASIS: Overall Anxiety Severity and Impairment Scale
OELs: occupational exposure limits
OR: odds ratio
PAF: population attributable fraction
PAM: Precaution Adoption Model
PANAS: Positive and Negative Affective Schedule
PANSS: Positive and Negative Syndrome Scale
PATH: Population Assessment of Tobacco and Health
PCHQR: PPS-Exempt Cancer Hospital Quality Reporting
PheT: phenanthrene tetraol
PM: particulate matter
PMTA: Premarket Tobacco Product Application
ppm: parts per million
PPS: prospective payment system
PROP: propylthiouracil
PSCDI: Penn State Cigarette Dependence Index
PSS: Perceived Stress Scale
PTC: phenylthiocarbamide
PTSD: posttraumatic stress disorder
QIDS: Quick Inventory of Depressive Symptomatology
QSU: Questionnaire on Smoking Urges-short form
RCT: randomized clinical trial
RELS: recommended exposure limits
RIFM: Research Institute for Fragrance Materials
RNC: reduced-nicotine-content
RR: relative risk
RR: risk ratio
SAF: smoking-attributable fraction
SAMHSA: Substance Abuse and Mental Health Services Administration
SAMMEC: Smoking-Attributable Mortality, Morbidity, and Economic Costs
SANS: Scale for Assessment of Negative Symptoms
SAVM: Smoking and Vaping Model
SBIRT: Screening, Brief Intervention, and Referral to Treatment
SD: standard deviation
SE: standard error
SEM: standard error of the mean
SES: socioeconomic status
SFNTC: Santa Fe Natural Tobacco Company
SGM: sexual and gender minority
SM: sexual minority
SNAP: Supplemental Nutrition Acceptance Program
SNP: single nucleotide polymorphism
SSN: Social Security number
TCPT: Tobacco Control Policy Tool
TLVs: threshold limit values
TNE: total nicotine equivalents
TPSAC: Tobacco Products Scientific Advisory Committee
TRP: transient receptor potential
TRPA1: transient receptor potential ankyrin 1
TRPM8: transient receptor potential melastatin 8
TUS-CPS: Tobacco Use Supplement to the Current Population Survey
UNC: usual-nicotine-content
USDHEW: U.S. Department of Health, Education, and Welfare
USDHHS: U.S. Department of Health and Human Services
USSTC: U.S. Smokeless Tobacco Company
VA: U.S. Department of Veterans Affairs
VLNC: very-low-nicotine-content
WHO: World Health Organization
WIC: Women, Infants, and Children
WISDM: Wisconsin Inventory of Smoking Dependence Motives
WS: Wilkinson Sword
YLD: years of life lived with disability or injury
YLL: years of life lost
YRBS: Youth Risk Behavior Survey
YRBSS: Youth Risk Behavior Surveillance System