# References

Alcohol, Drug Abuse, and Mental Health Administration (1989) Report of the Secretary's Task Force on Youth Suicide: Vols. 1-4 (DHHS Publication No. ADM 89-1624) , Washington, DC. U.S. Government Printing Office
American Academy of Pediatrics. Policy statement: Children, adolescents and television. Pediatrics,. (1990);85:1119-1120.
American Academy of Pediatrics Committee on Adolescence. Firearms and adolescents. Pediatrics,. (1992);89:784-87.
Angst, J., Angst, F., & Stassen, H.H. (1999) Suicide risk in patients with major depressive disorder Journal of Clinical Psychiatry 60 (Suppl. 2)57 62
Appleby, L., Shaw, J., Amos, T., McDonnell, R., Davies, S., Harris, C., McCann, K., Firth, C., & Douglas, A. (1997) The national confidential inquiry into suicide and homicide by people with mental illness. Progress report 1997. , LondonDepartment of Health
Atwood, K., Colditz, G.A., & Kawachi, I. From public health science to prevention policy: Placing science in its social and political contexts. American Journal of Public Health. (1997);87:1603-1605.
Bailley, S.E., Kral, M., & Dunham, K. Survivors of suicide do grieve differently: Empirical support for a common sense proposition. Suicide and Life- Threatening Behavior. (1999);29:256-271.
Baldessarini, R., Tondo, L, & Hennen, J. Effects of lithium treatment and its discontinuation on suicidal behavior in bipolar manic-depressive disorders. Journal of Clinical Psychiatry,. (1999);60:77-84.
Barraclough, B., Bunch, J., Nelson, B., & Sainsbury, P. A hundred cases of suicide: Clinical aspects. British Journal of Psychiatry. (1974);125:355-373.
Barrios, L.C., Everett, S.A., Simon, T.R., & Brener, N.D. Suicide ideation among U.S. college students: Associations with other injury risk behaviors. Journal of American College Health. (2000);48:229-233.
Beautrais, A.L., Coggan, C.A., Fergusson, D.M., & Rivers, L. (1997) The prevention, recognition and management of young people at risk of suicide: Development of guidelines for schools , WellingtonNew Zealand Ministry of Education.
Beautrais, A.L., Joyce, P.R., & Mulder, R.T. Psychiatric contacts among youths aged 13 through 24 years who have made serious suicide attempts. Journal of the American Academy of Child and Adolescent Psychiatry. (1998);37:504-511.
Berman, A.L. (1989) In M.L. Rosenberg & K. Baer (Eds.), Report of the Secretary's Task Force on Youth Suicide: Vol. 4. Strategies for the prevention of youth suicide (DHHS Publication No. ADM 89 1624, pp, Washington,, DC. U.S. Government Printing Office.
Berman, A.L. (1993) In A.S. Leenaars, A.L. Berman, P. Cantor, R.L. Litman, & R.W. Maris (Eds.), Suicidology: Essays in honor of Edwin S. Shneidman (pp. 248 267), Northvale,, NJ. Jason Aronson.
Birckmayer, J., & Hemenway, D. Minimum-age drinking laws and youth suicide, 1970-1990. American Journal of Public Health. (1999);89,:1365-1368.
Bongar, B., Berman, A.L., Maris, R.W., Silverman, M.M., Harris, E.A., & Packman, W.L. (Eds.). (1998) Risk management with suicidal patients. , New YorkGuilford Press.
Bongar, B., & Harmatz, M. Clinical psychology in graduate education in the study of suicide: Availability, resources, and importance. Suicide and Life- Threatening Behavior. (1991);21,:231-244.
Bongar, B., Lomax, J.W., & Harmatz, M. (1992) In B. Bongar (Ed.), Suicide: Guidelines for assessment, management, and treatment (pp. 253 267), New YorkOxford University Press.
Bonner, R.L. (1992) In R.W. Maris, A.L. Berman, J.T. Maltsberger, & R.I. Yufit (Eds.), Assessment and prediction of suicide (pp.398 419), New YorkGuilford Press.
Bonner, R.L. Correctional suicide prevention in the year 2000 and beyond. Suicide and Life-Threatening Behavior. (2000);30,:370-376.
Bonnie, R.J., Fulco, C.E., & Liverman, C.T. (Eds.). (1999) Reducing the burden of injury: Advancing prevention and treatment. , Washington,, DC. Institute of Medicine, National Academy Press.
Brener, N.D., Hassan, S.S., & Barrios, L.C. Suicidal ideation among college students in the United States. Journal of Consulting and Clinical Psychology. (1999);67,:1004-1008.
Brener, N.D., Krug, E.G., & Simon, T.R. Trends in suicidal ideation and behavior among high school students in the United States, 1991-1997. Suicide and Life-Threatening Behavior. (2000);30,:304-312.
Brent, D.A., Johnson, B.A., Perper, J., Connolly, J., Bridge, J., Bartle, S., & Rather, C. Personality disorder, personality traits, impulsive violence, and completed suicide in adolescents. Journal of the American Academy of Child and Adolescent Psychiatry. (1994);33,:1080-1086.
Brent, D.A., Perper, J.A., & Allman, C. Alcohol, firearms, and suicide among youth: Temporal trends in Allegheny County, Pennsylvania, 1960-83. Journal of the American Medical Association. (1987);257,:3369-3372.
Brent, D.A., Perper, J.A., Allman, C.J., Moritz, G.M., & Wartella, M.E. The presence and accessibility of firearms in the homes of adolescent suicides: A case-control study. Journal of the American Medical Association. (1991);266,:2989-2995.
Brent, D.A., Perper, J.A., Goldstein, C.E., Kolko, D.J., Allan, M.J., Allman, C.J., & Zelenak, J.P. Risk factors for adolescent suicide: A comparison of adolescent suicide victims with suicidal inpatients. Archives of General Psychiatry. (1988);45,:581-588.
Brent, D.A., Perper, J.A., Moritz, G., Baugher, M., Roth, C., Balach, L., & Schweers, J. Stressful life events, psychopathology, and adolescent suicide: A case control study. Suicide and Life-Threatening Behavior. (1993a);23,:179-187.
Brent, D.A., Perper, J.A., Moritz, G., Baugher, M., Schweers, J., & Roth, C. Firearms and adolescent suicide: A community case-control study. American Journal of Diseases of Children. (1993b);147,:1066-1071.
Bruce, M.L., & Pearson, J.L. Designing an intervention to prevent suicide: PROSPECT (Prevention of suicide in primary care elderly: Collaborative trial). Dialogues in Clinical Neuroscience. (1999);1,:100-112.
Bureau of Justice Statistics. (1995) Jails and jail inmates, 1993-1994. , Washington,, DC. U.S. Department of Justice.
Caine, E.D., Lyness, J.M., & Conwell, Y. Diagnosis of late-life depression: Preliminary studies in primary care settings. American Journal of Geriatric Psychiatry. (1996);4:S45-S50.
Caldwell, C.B., & Gottesman, I.I. Schizophrenics kill themselves too: A review of risk factors for suicide. Schizophrenia Bulletin. (1990);4,:571-589.
Callahan, J. Predictors and correlates of bereavement in suicide support group participants. Suicide and Life-Threatening Behavior. (2000);30,:104-124.
Catalano, R.F., Berglund, M.L., Ryan, J.A.M., Lonczak, H.C., & Hawkins, J.D. (1998) Positive youth development in the United States: Research findings on evaluations of positive youth development programs (NICHD Publication) , Washington,, DC. U.S. Department of Health and Human Services.
Centers for Disease Control. (1988) National mortality statistics [On-line] , Availablehttp://www.cdc.gov/ncipc/osp/usmort.htm
Centers for Disease Control. (1992) Youth suicide prevention programs: A resource guide. , Atlanta,, GA.
Centers for Disease Control. (1998) Ten leading causes of death for the United States [On-line] , Availablehttp://www.cdc.gov/ncipc
Centers for Disease Control. Suicide prevention among active duty Air Force personnel - United States, 1990-1999. Morbidity and Mortality Weekly Report. (1999);48,:1053-1057.
Centers for Disease Control. Youth risk behavior surveillance-United States, 1999. Morbidity and Mortality Weekly Report. (2000a);49:1-96.
Centers for Disease Control. Cluster of suicides and suicide attempts-New Jersey. Morbidity and Mortality Weekly Report. (1988);37,:213-216.
Children's Safety Network. (2000) Fact sheets: Youth suicide prevention plans. , Newton,, MA. Education Development Center.
Clark, D.C., & Horton-Deutsch, S.L. (1992). Assessment in absentia: The value of the psychological autopsy method for studying antecedents of suicide and predicting future suicides. In R.W. Maris, A.L. Berman, J.T. Maltsberger, & R.I. Yufit (Eds.) The assessment and prediction of suicide (pp , 144-182). New YorkGuilford Press.
Condelli, W.S., Bradigan, B., & Holanchock, H. Intermediate care programs to reduce risk and better manage inmates with psychiatric disorders. Behavioral Science Law. (1997);15,:459-467.
Conwell, Y. (1996) Diagnosis and treatment of depression in late life. , Washington,, DC. American Psychiatric Press.
Conwell, Y. Suicide in later life. Suicide and Life-Threatening Behavior. (2001);31:27-41.
Conwell, Y., & Brent, D. Suicide and aging I: Patterns of psychiatric diagnosis. International Psychogeriatrics. (1995);7,:149-164.
Conwell, Y.C., Duberstein, P.R., Cox, C., Herrmann, J.H., Forbes, N.T., & Caine, E.D. Relationships and age of Axis I diagnoses in victims of completed suicides: A psychological autopsy study. American Journal of Psychiatry. (1996);153,:1001-1008.
Cox, J.F., & Morschauser, P.C. A solution to the problem of jail suicide. Crisis. (1997);18,:178-184.
Crosby, A.E., Cheltenham, M.P., & Sacks, J.J. Incidence of suicidal ideation and behavior in the United States, 1994. Suicide and Life-Threatening Behavior. (1999);29,:131-139.
Davidson, L., & Gould, M.S. (1989) In L. Davidson & M. Linnoila (Eds.), Report of the Secretary's Task Force on Youth Suicide: Vol. 2. Risk factors for youth suicide (DHHS Publication No. ADM 89 1624, pp, Washington,, DC. U.S. Government Printing Office.
Diekstra, R.F.W. (1982) In J. Wilmott & J. Mendlewicz (Eds.), Bibliotheca Psychiatrica. New trends in suicide prevention (pp. 1 16), New YorkKarger.
Duberstein, P.R., Conwell, Y., Seidlitz, L., Denning, D.G., Cox, C., & Caine, E.D. Personality traits and suicidal behavior and ideation in depressed inpatients 50 years of age and older. Journal of Gerontology. (2000);55B,:18-26.
Durkheim E. (1897/1951) Suicide: A study in sociology (J.A , Spaulding & G. Simpson, Trans.). New YorkFree Press.
Eddy, D.M., Wolpert, R.L., & Rosenberg, M.L. (1989) In M.L. Rosenberg & K. Baer (Eds.), Report of the Secretary's Task Force on Youth Suicide: Vol. 4. Strategies for the prevention of youth suicide (DHHS Publication No. ADM 89 1624, pp, Washington,, DC. U.S. Government Printing Office.
Education Development Center. (1999) Questions commonly asked about ecodes [On-line] , Availablehttp://www.edc.org
Eggert, L.L., Thompson, E.A., Herting, J.R., & Nicholas, L.J. Reducing suicide potential among high-risk youth: Tests of a school-based prevention program. Suicide and Life-Threatening Behavior. (1995);25,:276-296.
Ellis, T.E., & Dickey, T.O. Procedures surrounding the suicide of a trainee's patient: A national survey of psychology internships and psychiatry residency programs. Professional Psychology: Research and Practice. (1998);29,:492-497.
Ellis, T.E., Dickey, T.O., & Jones, E.C. Patient suicide in psychiatry residency programs: A national survey of training and postvention practices. Academic Psychiatry. (1998);22,:181-189.
Evangelical Lutheran Church in America. (1999) A message on suicide prevention , Chicago,, IL.
Felner, R.D., Felner, T.Y., & Silverman, M.M. (2000) In J. Rapaport & E. Seidman (Eds.), Handbook of community psychology (pp. 9 42), New YorkPlenum Press.
Fenton, W.S. Depression, suicide and suicide prevention in schizophrenia. Suicide and Life-Threatening Behavior. (2000);30,:34-39.
Findling, R.L., Reed, M.D., & Blumer, J.L. Pharmacological treatment of depression in children and adolescents. Pediatric Drugs. (1999);1,:161-182.
Foster, T., Gillespie, K., McClelland, R., & Patterson, C. Risk factors for suicide independent of DSM-II-R Axis I disorder. British Journal of Psychiatry. (1999);175,:175-179.
Garland, A., Shaffer, D., & Whittle, B. A national survey of adolescent suicide prevention programs. Journal of the American Academy of Child and Adolescent Psychiatry. (1989);28,:931-934.
Garland, A.F., & Zigler, E. Adolescent suicide prevention: Current research and social policy implications. American Psychologist. (1993);48,:169-182.
Gibbs, J.T. Conceptual, methodological, and sociocultural issues in black youth suicide: Implications for assessment and early intervention. Suicide and Life-Threatening Behavior. (1988);18,:73-89.
Goldman, L.S., Silverman, M.M., & Alpert, E. (1998) In L.S. Goldman, T.N. Wise, & D.S. Brody (Eds.), Psychiatry for primary care physicians (pp. 155 180), Chicago,, IL. American Medical Association.
Goldman, L.S., Wise, T.N., & Brody, D.S. (Eds.). (1998) Psychiatry for primary care physicians. , Chicago,, IL. American Medical Association.
Gordon, R.S. An operational classification of disease prevention. Public Health Reports. (1983);98,:107-109.
Gould, M.S. Suicide and the media. Annals of the New York Academy of Sciences. (2001).
Gould, M.S., Wallenstein, S., Kleinman, M.H., O'Carroll, P.W., & Mercy, J.A. Suicide clusters: An examination of age-specific effects. American Journal of Public Health. (1990);80,:211-212.
Grossman, J.A., Hirsch, J., Goldenberg, D., Libby, S., Fendrich, M., Mackesy- Amiti, M., Mazur, C., & Hill-Chance, G. Strategies for school-based response to loss: Proactive training and postvention consultation. Crisis. (1995);16,:18-26.
Grossman, J.A., & Kruesi, M.J.P. (2000) In R.W. Maris, S.S. Canetto, J.L. McIntosh, & M.M. Silverman (Eds.), Review of Suicidology (pp. 170 201), New YorkGuilford Press.
Harris, E.D., & Barraclough, B. Suicide as an outcome for mental disorders. British Journal of Psychiatry. (1997);170,:205-228.
Hawton, K., Arensman, E., Townsend, E., Bremner, S., Feldman, E., Goldney, R., Gunnell, D., Hazell, P., van Heeringen, K., House, A., Owens, D., Sakinofsky, I., & Traskman-Bendz, L. Deliberate self-harm: Systematic review of efficacy of psychosocial and pharmacological treatments in preventing repetition. British Medical Journal. (1998);317,:441-447.
Hawton, K., & von Heeringen, K. (Eds.). (2000) The international handbook of suicide and attempted suicide. , Chichester,John Wiley & Sons.
Hawton, K., Simkin, S., Deeks, J.J., O'Connor, S., Keen, A., Altman, D.G., Philo, G., & Bulstrode, C. Effects of a drug overdose in a television drama on presentations to hospital for self-poisoning: Time series and questionnaire study. British Medical Journal. (1999);318,:972-977.
Hayes, L.M. (1995) Prison Suicide: An overview and guide to prevention. , Washington,, D.C.. U.S. Department of Justice, National Institute of Corrections.
Hayes, L.M. From chaos to calm: One jail system's struggle with suicide prevention. Behavioral Sciences & the Law. (1997);15,:399-413.
Hayes, L.M. Suicide in adult correctional facilities: Key ingredients to prevention and overcoming the obstacles. Journal of Law, Medicine, and Ethics. (1999);27,:260-268.
Hayes, L.M., & Rowan, J.R. (1988) National study of jail suicides: Seven years later , Alexandria,, VA. National Center for Institutions and Alternatives.
Hazell, P., & King, R. Arguments for and against teaching suicide prevention in schools. Australian/New Zealand Journal of Psychiatry. (1996);30,:633-642.
Henriksson, M.M., Aro, H.M., Marttunen, M.J., Heikkinen, M., Isometsa, E.T., Kuoppasalmi, K.I., & Lonnqvist, J.K. Mental disorders and comorbidity in suicide. American Journal of Psychiatry. (1993);150,:935-940.
Herman, J.L. (1997) Trauma and recovery. , New YorkBasic Books.
Hopkins, D.D., Grant-Worley, J.A., & Fleming, D.W. Fatal and nonfatal suicide attempts among adolescents-Oregon, 1988-1993. Morbidity and Mortality Weekly Report. (1995);44,:312-323.
Hoyert, D.L., Kochanek, K.D., & Murphy, S.L. (1999) Deaths: Final data for 1997. National Vital Statistics Reports: Vol. 47 (9). , Hyattsville,, MD. National Center for Health Statistics.
Hoyt, D.R., Conger, R.D., Valde, J.G., & Weihs, K. Psychological distress and help seeking in rural America. American Journal of Community Psychology. (1997);25,:449-470.
Indian Health Service. (1997). Trends in Indian health 1997 [On-line]. http://www.ihs.gov/PublicInfo/Publications/trends97/trends97.asp.
Inskip, H.M., Harris, E.C., & Barraclough, B. Lifetime risk of suicide for affective disorder, alcoholism and schizophrenia. British Journal of Psychiatry. (1998);172,:35-7.
International Association for Suicide Prevention. International Association for Suicide Prevention (IASP) guidelines for suicide prevention. Crisis. (1999);20,:155-163.
Isacsson, G., Holmgren, P., Druid, H., & Bergman, U. The utilization of antidepressants: A key issue in the prevention of suicide: An analysis of 5281 suicides in Sweden during the period 1992-1994. Acta Psychiatrica Scandinavica. (1997);96,:94-100.
Jacobs, D.G. (Ed.). (1999a) The Harvard Medical School guide to suicide assessment and intervention. , San FranciscoJossey-Bass.
Jacobs, D.G. Depression screening as an intervention against suicide. Journal of Clinical Psychiatry. (1999b);60:42-45.
Jamison, K .R. (1999) Night falls fast: Understanding suicide , New YorkAlfred A. Knopf
Jamison, K.R (2000) Suicide and bipolar disorder Journal of Clinical Psychiatry 61(Suppl. 9)47 51
Jamison, K.R., & Baldessarini, R.J. (Eds.) (1999) Effects of medical interventions on suicidal behavior Journal of Clinical Psychiatry 60(Suppl. 2).
Jobes, D.A., Berman, A.L., O'Carroll, P.W., Eastgard, S., & Knickmeyer, S. The Kurt Cobain suicide crisis: Perspectives from research, public health, and the news media. Suicide and Life-Threatening Behavior. (1996);26,:260-269.
Joe, S., & Kaplan, M.S. Suicide among African-American men. Suicide and Life Threatening Behavior. (2001);31:106-121.
Kalafat, J., & Elias, M. An evaluation of school-based suicide awareness intervention. Suicide and Life-Threatening Behavior. (1994);24,:224-233.
Kalafat, J., & Elias, M.J. Suicide prevention in an educational context: Broad and narrow foci. Suicide and Life-Threatening Behavior. (1995);25,:123-133.
Kalafat, J., & Ryerson, D.M. The implementation and institutionalization of a school-based youth suicide prevention program. Journal of Primary Prevention. (1999);19,:157-175.
Kazdin, A.E., Holland, L., & Crowley, M. Family experience of barriers to treatment and premature termination from child therapy. Journal of Consulting and Clinical Psychology. (1997);65,:453-463.
Kellermann, A.L., Rivara, F.P., Somes, G., Reay, T., Francisco, J., Banton, J.G., Prodzinski, J., Fligner, C., & Hackman, B.B. Suicide in the home in relation to gun ownership. New England Journal of Medicine. (1992);327,:467-472.
Kelly, S., & Bunting, J. Trends in suicide in England and Wales, 1982-1996. Population Trends. (1998);92,:29-41.
Kessler, R.C., Nelson, C.B., McKinagle, K.A., Edlund, M.J., Frank, R.G., & Leaf, P.L. The epidemiology of co-occurring addictive and mental disorders: Implications for prevention and service utilization. American Journal of Orthopsychiatry. (1996);66,:17-31.
King, A., Kovan, R., London, R., & Bongar, B. Toward a standard of care for treating suicidal outpatients: A survey of social workers' beliefs about appropriate treatment behaviors. Suicide and Life-Threatening Behavior. (1999);29,:347-352.
Kleespies, P.M. (Ed.). (1998) Emergencies in mental health practice: Evaluation and management. , New YorkGuilford Press.
Knickmeyer, S. Commentary -- the media perspective. Suicide and Life-Threatening Behavior. (1996);26,:269-271.
Koerner, K., & Linehan, M.M. Research on dialectical behavior therapy for patients with borderline personality disorder. Psychiatric Clinics of North America. (2000);23,:151-167.
Kreitman, N. The coal gas story: United Kingdom suicide rates, 1960-1971. British Journal of Preventative and Social Medicine. (1976);30,:86-93.
Lewinsohn, P.M., & Clarke, G.N. Psychosocial treatments for adolescent depression. Clinical Psychology Review. (1999);19,:329-342.
Linehan, M.M. Suicidal people: One population or two?. Annals of the New York Academy of Sciences. (1986);487,:16-33.
Linehan, M.M. Behavioral treatments of suicidal behaviors. Annals of the New York Academy of Sciences. (1997);836,:302-328.
Linehan, M.M., Heard, H.L., & Armstrong, H.E. Naturalistic follow-up of a behavioral treatment for chronically parasuicidal borderline patients. Archives of General Psychiatry. (1993);50,:971-974.
Litts, D., Moe, K., Roadman, C., Janke, R., & Miller, J. Suicide prevention among active duty Air Force personnel -- United States, 1990-1999. Morbidity and Mortality Weekly Report. (1999);48,:1053-1057.
MacKay, D.W. Evidence preservation and collection. Where does EMS fit in?. Emergency Medical Services. (1997);26:50-56.
Mann, J.J. The neurobiology of suicide. Nature Medicine. (1998);4,:25-30.
Maris, R.W., Berman A.L., Maltsberger, J.T., & Yufit, R.I. (Eds.). (1992) Assessment and prediction of suicide. , New YorkGuilford Press.
Maris, R.W., Berman, A.L., & Silverman, M.M. (2000) Comprehensive textbook of suicidology. , New YorkGuilford Press.
Marzuk, P.M., Leon, A.C., Tardiff, K., & Morgan, E.B. The effect of access to lethal methods of injury on suicide rates. Archives of General Psychiatry. (1992);49,:451-458.
McDaniel, J.S., Purcell, D.W., & D'Augelli, A.R. The relationship between sexual orientation and risk for suicide: Research findings and future directions for research and prevention. Suicide and Life-Threatening Behavior. (2001);31:84-105.
Meltzer, H.Y. Suicide and schizophrenia: Clozapine and the InterSePT study. International Clozaril/Leponex suicide prevention trial. Journal of Clinical Psychiatry. (1999);60:47-50.
Meltzer, H.Y., & Okayli, G. Reduction in suicidality during clozapine treatment of neuroleptic-resistant schizophrenia: Impact on risk-benefit assessment. American Journal of Psychiatry. (1995);152,:183-190.
Metha, A., Weber, B., & Webb, L.D. Youth suicide prevention: A survey and analysis of policies and efforts in the 50 states. Suicide and Life-Threatening Behavior. (1998);28,:150-164.
Middlebrook, D.L., LeMaster, P.L., Beals, J., Novins, D.K., & Manson, S.M. Suicide prevention in American Indian and Alaskan Native communities: A critical review of programs. Suicide and Life-Threatening Behavior. (2001);31:132-149.
Miller, D.N., Eckert, T.L., DuPaul, G.J., & White, G.P. Adolescent suicide prevention: Acceptability of school-based programs among secondary school principals. Suicide and Life-Threatening Behavior. (1999);29,:72-85.
Miller, T., Covington, K., & Jensen, A. (1999) In S. Mulder & E.F. van Beeck (Eds.), Proceedings of a conference in Noordwijkerhout, May 13-15, 1998 (pp. 23 40), . AmsterdamEuropean Consumer Safety Association.
Montgomery, S.A. Suicide and antidepressants. Annals of the New York Academy of Sciences. (1997);286,:329-336.
Morgan, H.G., & Stanton, R. Suicide among psychiatric inpatients in a changing clinical scene. British Journal of Psychiatry. (1997);171,:561-563.
Móscicki, E.K. Identification of suicide risk factors using epidemiologic studies. Psychiatric Clinics of North America. (1997);20,:499-517.
Mrazek, P.J., & Haggerty, R.J. (Eds.). (1994) Reducing risks for mental disorders: Frontiers for preventive intervention research. , Washington,, DC. National Academy Press.
Murphy, G.E. The physician's responsibility for suicide. I. An error of commission. Annals of Internal Medicine. (1975a);82,:301-304.
Murphy, G.E. The physician's responsibility for suicide. II. Errors of omission. Annals of Internal Medicine. (1975b);82,:305-309.
Murphy, G.E. (1992) Suicide in alcoholism. , New YorkOxford University Press.
Murphy, G.E. (2000) In K. Hawton & K. van Heeringen (Eds.), The international handbook of suicide and attempted suicide (pp. 135 146), Bognor RegisEngland: John Wiley & Sons.
National Center for Health Statistics. (1997) Vital Statistics of the United States, Monthly Report: Vol. 45. , Washington,, DC. U.S. Government Printing Office.
National Institute on Alcohol Abuse and Alcoholism. New advances in alcoholism treatment. Alcohol Alert. (2000).
National Institute on Drug Abuse. (1999) Principles of drug addiction treatment: A research-based guide. , Washington, D.C.
Neimeyer, R.A. Suicide and hastened death: Toward a training agenda for counseling psychology. The Counseling Psychologist. (2000);28,:551-560.
New Zealand Ministry of Education and National Health Committee. (1998) Young people at risk of suicide: A guide for schools. , Wellington
O'Carroll, P.W. Validity and reliability of suicide mortality data. Suicide and Life-Threatening Behavior. (1989);19,:1-16.
O'Carroll, P.W. Commentary. Suicide and Life-Threatening Behavior. (1996);26,:264-269.
O'Carroll, P.W., Berman, A.L., Maris, R.W., Móscicki, E.K., Tanney, B.L., & Silverman, M.M. Beyond the tower of Babel: A nomenclature for suicidology. Suicide and Life-Threatening Behavior. (1996);26,:237-252.
O'Carroll, P.W., Mercy, J.A., Hersey, J.C., Boudreau, C., & Odell-Butler, M. (1992) Centers for Disease Control youth suicide prevention programs: A resource guide. , Atlanta,, GA. Centers for Disease Control.
O'Carroll, P.W., & Potter, L.B. (1994) Suicide contagion and the reporting of suicide: Recommendations from a national workshop Morbidity and Mortality Weekly Report 42 (RR-6)9 17
O'Carroll, P.W., & Silverman, M.M. Community suicide prevention: The effectiveness of bridge barriers. Suicide and Life-Threatening Behavior. (1994);24,:89-99.
Olds, D., Henderson, C.R., Cole, R., Eckenrode, J., Kitzman, H., Luckey, D., Pettitt, L., Sidora, K., Morris, P., & Powers, J. Long-term effects of nurse home visitation on children's criminal and antisocial behavior: 15-year follow-up of a randomized controlled trial. Journal of the American Medical Association. (1998);280,:1238-1244.
Oquendo, M.A., Malone, K.M., Ellis, S.P., Sackeim, H.A., & Mann, J.J. Inadequacy of antidepressant treatment for patients with major depression who are at risk for suicidal behavior. American Journal of Psychiatry. (1999);156,:190-194.
Palmer, C.S., Revicki, D.A., Halpern, M.T., & Hatziandreu. E.J (1995) The cost of suicide and suicide attempts in the United States Clinical Neuropharmacology 18(Suppl. 3)S25 S33
Patton, M.Q. (1997) Utilization-focused evaluation (3rd ed.) , Thousand Oaks,, CA. Sage.
Peters, K.D., Kochanek, K.D., Murphy, S.L (1998) National vital statistics reports: Vol. 47(9). , Hyattsville,, MD. National Center for Health Statistics.
Phillips, D.P. The Werther effect: Suicide and other forms of violence are contagious. Science. (1985);25,:32-39.
Phillips, D.P., Lesyna, M.A., & Paight, D.J. (1992) In R.W. Maris, A. L. Berman, J.T. Maltsberger, & R. I. Yufit (Eds.), Assessment and prediction of suicide (pp. 499 519), New YorkGuilford Press.
Piacentini, J., Rotheram-Borus, M.J., Gillis, J.R., Graae, F., Trautman, P., Cantwell, C., Gracialeeds, C., & Shaffer, D. Predictors of treatment attendance among adolescent suicide attempters. Journal of Consulting and Clinical Psychology. (1995);63,:469-473.
Pirkis, J., Burgess, P. Suicide and recency of health care contacts: A systematic review. British Journal of Psychiatry. (1998);173,:462-474.
Plutchik, R., & van Praag, H.M (1994) In M. Hillbrand & N.J. Pollone (Eds.), The psychobiology of aggression. , Binghamton, NY. Haworth Press.
Potter, L., Powell, K.E., & Kachur, S.P. Suicide prevention from a public health perspective. Suicide and Life-Threatening Behavior. (1995);26,:82-91.
Potter, L.B., Rosenberg, M.L., & Hammond, W.R. Suicide in youth: A public health framework. Journal of the American Academy of Child and Adolescent Psychiatry. (1998);37,:484-487.
Radeck, T (undated) Suicides on television. , Champaign, IL. National Coalition on Television Violence.
Ramsay, R.F., & Tanney, B.L. (Eds.). (1996) Global Trends in Suicide Prevention: Toward the Development of National Strategies for Suicide Prevention. , BombayTata Institute of Social Sciences.
Rich, C. L., Young, D., & Fowler R. C. San Diego suicide study: Young vs. old subjects. Archives of General Psychiatry. (1986);43,:577-582.
Richman, J. (1980) Family therapy for suicidal people. , New YorkSpringer.
Risk Management Foundation of the Harvard Medical Institutions. (1996) Guidelines for identification, assessment, and treatment planning for suicidality [On-line] http://www.rmf.harvard.edu/rmLibrary/clinical-guidelines/suicide/index.html
Roberts, R.E., Chen, Y.R., & Roberts, C.R. Ethnocultural differences in prevalence of adolescent suicidal behaviors. Suicide and Life-Threatening Behavior. (1997);27,:208-217.
Robins, E. (1981) The final months. , New YorkOxford University Press.
Rosenberg, M.L., Gelles, R.J., Holinger, P.C., Zahn, M.A., Stark, E., Conn, J.M., Fajman, N.N., & Karlson, T.A (1987) In R.W. Amler & H.B. Dull (Eds.), American Journal of Preventive Medicine: Vol. 3 (Suppl.). Closing the gap: The burden of unnecessary illness. , New YorkOxford University
Rotheram-Borus, M.J., Piacentini, J., Van Rossem, R., Grace, F., Cantwell, C., Castro-Blanco, D., & Feldman, J. Treatment adherence among Latina female adolescent suicide attempters. Suicide and Life-Threatening Behavior. (1999);29,:319-331.
Rotheram-Borus, M.J., Piacentini, J., Cantwell, C., Belin, T.R., & Song, J. The 18-month impact of emergency room intervention for adolescent female suicide attempters. Journal of Consulting and Clinical Psychology. (2000);68,:1081-1093.
Rudd, M.D. (2000) In R.W. Maris, S.S. Canetto, J.L. McIntosh, & M.M. Silverman (Eds.), Review of suicidology 2000 (pp. 47 83), New YorkGuilford Press.
Rudd, M.D., & Joiner, T. The assessment, management, and treatment of suicidality: Toward clinically informed and balanced standards of care. Clinical Psychology: Science and Practice. (1998);5,:135-150.
Rudd, M.D., Joiner, T.E., Jobes, D., & King, C. Practice guidelines in the outpatient assessment and treatment of suicidality: An integration of science and a recognition of its limitations. Professional Psychology: Research and Practice. (1998);30,:437-446.
Rudd, M.D., Joiner, T.E., & Rajab, M.H. (2000) Treating suicidal behavior: An effective, time-limited approach. , New YorkGuilford Press.
Rutz, W. Preventing suicide and premature death by education and treatment. Journal of Affective Disorders. (2001);62,:123-129.
Rutz, W., Walinder, J., Eberhard, G., Holmberg, T., von Knorring, A., von Knorring, L., Wistedt, B., & Aberg-Wistedt, A. An educational program on depressive disorders for general practitioners on Gotland: Background and evaluation. Acta Psychiatrica Scandinavica. (1989);79,:19-26.
Salive, M.E., Smith, G.S., & Brewer, T.F. Suicide mortality in the Maryland state prison system, 1979-1987. Journal of the American Medical Association. (1989);262,:365-369.
Sampson, R.J., Raudenbush, S.W., & Earls, F. Neighborhoods and violent crime: A multilevel study of collective efficacy. Science. (1997);277, 918-924. Satcher, D. (1998). Bringing the public health approach to the problem of suicide. Suicide and Life-Threatening Behavior, 28,:325-327.
Schmidtke, A., & Schaller, S. (1998) In D. DeLeo, A. Schmidtke, & R.F.W. Diekstra (Eds.), Suicide prevention: A holistic approach (pp. 121 137), Dordrecht, NetherlandsKluwer.
Schmidtke, A., & Schaller, S. (2000) In K. Hawton & K. van Heeringen (Eds.), The international handbook of suicide and attempted suicide (pp. 675 697), New YorkJohn Wiley & Sons.
Shaffer, D., & Craft, L. Methods of adolescent suicide prevention. Journal of Clinical Psychiatry. (1999);60:70-74.
Shea, S.C. (1999) The practical art of suicide assessment. , New YorkJohn Wiley & Sons.
Shneidman, E. The psychological pain assessment scale. Suicide and Life- Threatening Behavior. (1999);29,:287-294.
Shneidman, E.S., & Farberow N.L. The LA SPC: A demonstration of public health feasibilities. American Journal of Public Health. (1965);55,:21-26.
Silverman, M.M., Davidson L., & Potter, L. (Eds.) (2001) National suicide prevention conference background papers Suicide and Life-Threatening Behavior 31(1) (Suppl.).
Silverman, M.M., & Felner, R.D. Suicide prevention programs: Issues of design, implementation, feasibility, and developmental appropriateness. Suicide and Life-Threatening Behavior. (1995);25,:93-105.
Silverman, M.M., & Maris, R.W. (Eds.). (1995) Suicide prevention: Toward the year 2000. , New YorkGuilford Press.
Silverman, M.M., Meyer, P.M., Sloane, F., Raffel, M., & Pratt, D.M. The Big Ten student suicide study: A 10-year study of suicides on midwestern university campuses. Suicide and Life-Threatening Behavior. (1997);27,:285-303.
Simon, T.R., & Crosby, A.E. Suicide planning among high school students who report attempting suicide. Suicide and Life-Threatening Behavior. (2000);30,:213-221.
Spirito, A., Brown, L., Overholser, J., & Fritz, G. Attempted suicide in adolescence: A review and critique of the literature. Clinical Psychology Review. (1989);9,:335-363.
Stahl, S.M. (2000) Essential psychopharmacology: Neuroscientific basis and practical applications (2nd ed.) , CambridgeCambridge University Press.
Styron, W. (1990) Darkness visible: A memoir of madness. , New YorkRandom House.
Sussman, L.K., Robins, L.N., & Earls, F. Treatment-seeking for depression by black and white Americans. Social Science and Medicine. (1987);24,:187-196.
Tanney, B.L. (2000) In R.W. Maris, A.L. Berman, & M.M. Silverman (Eds.), Comprehensive textbook of suicidology (pp. 311 341), New YorkGuilford Press.
Taylor, S. J., Kingdom, D., & Jenkins, R. How are nations trying to prevent suicide? An analysis of national suicide prevention strategies. Acta Psychiatrica Scandinavica. (1997);95,:457-463.
Thacker, S.B., & Stroup, D.F. Future directions for comprehensive public health surveillance and health information systems in the United States. American Journal of Epidemiology. (1994);140,:383-397.
Thompson, E.A., & Eggert, L.L. Using the suicide risk screen to identify suicidal adolescents among potential high school dropouts. Journal of the American Academy of Child Adolescent Psychiatry. (1999);38,:1506-1514.
Tondo, L., Jamison, K.R., & Baldessarini, R.J. Effect of lithium maintenance on suicidal behavior in major mood disorders. Annals of the New York Academy of Sciences. (1997);286,:339-351.
Uba, L. (1994) Asian Americans: Personality patterns, identity, and mental health. , NYGuilford Press.
United Nations/World Health Organization. (1996) Prevention of Suicide: Guidelines for the formulation and implementation of national strategies (ST/ESA/245) , GenevaWorld Health Organization.
U.S. Department of Health and Human Services. (1999) Mental health: A report of the Surgeon General. , Rockville,, MD. U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Center for Mental Health Services, National Institutes of Health, National Institute of Mental Health.
U.S. Department of Health and Human Services. (2000) Healthy people 2010 (2nd ed.) , Washington,, DC. U.S. Government Printing Office.
U.S. Public Health Service. (1999) The Surgeon General's call to action to prevent suicide. , Washington,, DC.
U.S. Public Health Service. (2001) Youth violence: A report of the Surgeon General. , Washington,, DC.
Upanne, M. A model for the description and the interpretation of suicide prevention. Suicide and Life-Threatening Behavior. (1999);29,:241-255.
Velting, D.M., & Gould M.S. (1997) In R.W. Maris, M.M. Silverman, & S.S. Canetto (Eds.), Annual review of suicidology (pp. 96 136), New YorkGuilford Press.
Vieland, V., Whittle, B., Garland, A., Hicks, R., & Shaffer, D.J. The impact of curriculum-based suicide prevention programs for teenagers: An 18-month follow-up. Journal of the American Academy of Child and Adolescent Psychiatry. (1991);30,:811-815.
Wasserman, I. Imitation and suicide: A reexamination of the Werther effect. American Sociological Review. (1984);49,:427-436.
Weiss, C.H. (1998) Evaluation methods for studying programs and policies (2nd ed.) , Upper Saddle River,, NJ. Prentice Hall.
West, M.A. Federal, state, and community partnerships to prevent youth suicides. Suicide and Life-Threatening Behavior. (1998);28,:143-146.
World Health Organization. (2000a) Preventing suicide: A resource for general physicians (WHO/MNH/MBD/00.1) , GenevaWorld Health Organization, Department of Mental Health.
World Health Organization. (2000b) Preventing suicide: A resource for media professionals (WHO/MNH/MBD/00.2) , GenevaWorld Health Organization, Department of Mental Health.
World Health Organization. (2000c) Preventing suicide: A resource for primary health care workers (WHO/MNH/MBD/00.4) , GenevaWorld Health Organization, Department of Mental Health.
World Health Organization. (2000d) Preventing suicide: A resource for prison officers (WHO/MNH/MBD/00.5) , GenevaWorld Health Organization, Department of Mental Health.
Wynne, E.A. (1989) In M.L. Rosenberg & K. Baer (Eds.), Report of the Secretary's Task Force on Youth Suicide: Vol.4. Strategies for the prevention of youth suicide (DHHS Publication No. ADM 89 1624, pp, Washington,, DC. U.S. Government Printing Office.
Youth Suicide By Firearms Task Force. Consensus Statement on youth suicide by firearms. Archives of Suicide Research. (1998);4,:89-94.
Zenere, F.J., III, & Lazarus, P.G. The decline of youth suicidal behavior in an urban, multicultural public school system following the introduction of a suicide prevention and intervention program. Suicide and Life-Threatening Behavior. (1997);24,:387-403.
Zimmerman, J.K., & Asnis, G.M. (Eds.). (1995) Treatment approaches with suicidal adolescents. , New YorkJohn Wiley & Sons.