# Foreword

Suicide is a particularly awful way to die: the mental suffering leading up to it is usually prolonged, intense, and unpalliated. There is no morphine equivalent to ease the acute pain, and death not uncommonly is violent and grisly. The suffering of the suicidal is private and inexpressible, leaving family members, friends, and colleagues to deal with an almost unfathomable kind of loss, as well as guilt. Suicide carries in its aftermath a level of confusion and devastation that is, for the most part, beyond description. Kay Redfield Jamison

To most of those who have experienced it, the horror of depression is so overwhelming as to be quite beyond expression, hence the frustrated sense of inadequacy found in the work of even the greatest artists....If our lives had no other configuration but this, we should want, and perhaps deserve, to perish; if depression had no termination, then suicide would, indeed, be the only remedy. But one need not sound the false or inspirational note to stress the truth that depression is not the soul's annihilation; men and women who have recovered from the disease - and they are countless - bear witness to what is probably its only saving grace: it is conquerable. William Styron

## Public Efforts Leading to the Goals and Objectives For Action

Suicide has stolen lives around the world and across the centuries. Meanings attributed to suicide and notions of what to do about it have varied with time and place, but suicide has continued to exact a relentless toll. Only recently have the knowledge and tools become available to approach suicide as a preventable problem with realistic opportunities to save many lives. The goals and objectives presented here, a cornerstone of our Nation's strategy to prevent suicide, are framed upon these advances in science and public health. Suicide is a serious public health problem.

The French social scientist, Emile Durkheim (1858-1917) developed a method of study that became the foundation for scientific inquiry about suicide. Instead of basing his conclusions only upon commonalities among people known to have died by suicide, Durkheim originated the scientific exploration of risk factors for suicide by comparing one group with another (Durkheim, 1897/1951). To Durkheim, the differences in rates of suicide could be attributed to distinguishing sociological characteristics among those population groups. Comparing those who are suicidal with those who are not, or groups having high rates of suicide with those having low rates is the incremental process by which risk and protective factors for suicide have been unveiled.

In the United States, large-scale efforts to prevent suicide began in 1958 through funds from the U.S. Public Health Service to establish the first suicide prevention center. Based in Los Angeles, Edwin Shneidman, Norman Farberow, and Robert Litman studied suicide in the context of providing community service and crisis intervention (Shneidman and Farberow, 1965). Other crisis intervention centers were founded across the country to replicate the Los Angeles Suicide Prevention Center's service component.

A more direct Federal role in suicide prevention began in 1966 when the Center for Studies of Suicide Prevention was established at the National Institute of Mental Health (NIMH). In time, this unit became the Suicide Research Unit (no longer existing) that championed the risk factor approach to suicide prevention, a central tenet in the public health model of prevention embodied in this National Strategy for Suicide Prevention (National Strategy or NSSP). During the next two decades, the American Association of Suicidology and then the American Foundation for Suicide Prevention were established. Among their activities these professional and private voluntary organizations worked to increase the scientific understanding of suicide as a base for effective prevention activities.

In 1983, the Centers for Disease Control and Prevention (CDC) established a violence prevention unit that brought to public attention a disturbing increase in youth suicide rates. In response, the Secretary of Health and Human Services established the multi-year public/private Secretary's Task Force on Youth Suicide to review what was known about risk factors for youth suicide and promising interventions. These reviews and the Task Force's prevention recommendations were published in 1989 (ADAMHA, 1989).

Shortly thereafter an international effort culminated in the United Nations/World Health Organization's 1996 summary, Prevention of Suicide: Guidelines for the Formulation and Implementation of National Strategies (UN/WHO, 1996). In the U.S., the Suicide Prevention Advocacy Network (SPAN USA), a grassroots advocacy organization including suicide survivors (persons close to someone who completed suicide), suicide attempt survivors, and community activists championed these guidelines as a way to encourage development of a national suicide prevention strategy for the United States. Their work to marshal social will for suicide prevention generated Congressional Resolutions recognizing suicide as a national problem and suicide prevention as a national priority. These resolutions provided further impetus to develop a national suicide prevention strategy.

SPAN propelled the creation of an innovative public/private partnership to jointly sponsor a National Suicide Prevention Conference convened in Reno, Nevada, in October 1998 (Reno Conference). Participating agencies within the U.S. Department of Health and Human Services were the Centers for Disease Control and Prevention, the National Institutes of Health, the Office of the Surgeon General, the Substance Abuse and Mental Health Services Administration, the Health Resources and Services Administration, the Indian Health Service and the Public Health Service Regional Health Administrators. Conference participants, including researchers, health, mental health and substance abuse clinicians, policy makers, suicide survivors, consumers of mental health services, and community activists and leaders discussed eight background papers that were commissioned to summarize the evidence base for suicide prevention (Silverman, Davidson, and Potter, 2001). Working in regional, multi- disciplinary groups, participants at the Reno Conference offered many recommendations for action that were shaped into a list of 81 by an expert panel.

Moving forward with the work of the Reno Conference, the Surgeon General issued his Call to Action to Prevent Suicide in July 1999, emphasizing suicide as a serious public health problem. (USPHS, 1999) The Surgeon General's Call introduced a blueprint for addressing suicide prevention through Awareness, Intervention, and Methodology (AIM), which describes 15 broad recommendations, containing goal statements, broad objectives, and recommendations for implementation, consistent with a public health approach to suicide prevention. AIM represents a consolidation of the highest-ranked of the 81 Reno Conference recommendations according to their scientific evidence, feasibility, and community support.

Continuing attention to suicide prevention issues and the significant role of mental health and substance abuse services in suicide prevention is reflected in the landmark Mental Health: A Report of the Surgeon General (DHHS, 1999) and in the nation's public health agenda, Healthy People 2010, (see Objectives 18-1 and 18-2)(DHHS, 2000). The effective implementation of the National Strategy will play a critical role in reaching the suicide prevention goals outlined in Healthy People 2010. In early 2000, the Secretary of Health and Human Services officially established the National Strategy Federal Steering Group (FSG) to, "...ensure resources identified...for the purpose of completing the National [Suicide Prevention] Strategy are coordinated to speed its progress." The FSG carefully reviewed the recommendations of both the Reno meeting and the Call to Action with a view to developing a comprehensive plan outlining national goals and objectives that would stimulate the subsequent development of defined activities for local, State and Federal partners.

The National Strategy Leadership Consultants (see Acknowledgments) met to identify the scope and priorities for these Goals and Objectives for Action. The Leadership Consultants have continued to refine the goals and objectives as part of a broadly inclusive process which has invited critical examination by scientific, clinical, and government leaders; other professionals; and the general public. Revised draft goals and objectives were also posted on the World Wide Web inviting comment. During 2000, public hearings on Goals and Objectives for Action were held in Atlanta, Boston, Kansas City, and Portland to provide a face-to-face forum for additional input and clarification.

Working in collaboration to develop the National Strategy has been a process that has promoted investment in the goal of suicide prevention and promoted broad collaboration in prevention activities. This volume, the National Strategy for Suicide Prevention: Goals and Objectives for Action, represents a significant milestone and continuing progress towards all of the elements in a planned national strategy.

## The National Strategy Concept

A national strategy to prevent suicide is a comprehensive and integrated approach to reducing the loss and suffering from suicide and suicidal behaviors across the life course. It encompasses the promotion, coordination, and support of activities that will be implemented across the country as culturally appropriate, integrated programs for suicide prevention among Americans at national, regional, tribal, and community levels.

A broad public/private partnership is essential for developing and implementing a national strategy. Interwoven within a national strategy are three key ingredients for action to improve suicide prevention: a knowledge base, the public will to support change and generate resources, and a social strategy to accomplish change. Developing a national strategy provides an opportunity to convene public and private partners across many sectors of society - government, public health, education, human services, religion, voluntary organizations, advocacy, and business - to sustain a true, national effort.

## Benefits of a National Strategy

A national strategy for suicide prevention can raise awareness and help make suicide prevention a national priority. This can help direct resources of all kinds to the issue.

A national strategy provides an opportunity to use public-private partnerships and the energy of survivors to engage those who may not have considered suicide prevention within their purview. It supports collaboration across a broad spectrum of agencies, institutions, groups, and community leaders as implementation partners.

A national strategy can link information from many prevention programs to avoid unintentional duplication and disseminate information about successful prevention interventions.

A national strategy can direct attention to measures that benefit the whole population and, by that means, reduce the likelihood of suicide before vulnerable individuals reach the point of danger.

Suicide is an outcome of complex interactions among neurobiological, genetic, psychological, social, cultural, and environmental risk and protective factors. Multiple risk and protective factors interact in suicide prevention. Development of a national strategy can bring together multiple disciplines and perspectives to create an integrated system of interventions across multiple levels, such as the family, the individual, schools, the community, and the health care system.

Collaborating in a national strategy can help develop priorities in an equitable way. Resources are always finite and priorities direct resources to projects that are likely to address the greatest needs and achieve the greatest benefits. Some types of expertise are not available across all communities. A national strategy can provide technical assistance with valuable types of expertise to strengthen community programs.

An evidence-based national strategy can maximize success when recommendations are implemented locally. Sound evaluation of community programs, in turn, builds the evidence base.

## Key Elements of a Planned National Strategy

A national strategy for the prevention of suicide has many interrelated elements contributing to success in reducing the toll from suicide.

- A means of engaging a broad and diverse group of partners to develop and implement the national strategy with the support of public and private social policies
- A sustainable and functional operating structure for partners with authority, funding, responsibility, and accountability for national strategy development and implementation
- Agreements among Federal agencies and institutions outlining and coordinating their appropriate segments of the national strategy
- A summary of the scope of the problem and consensus on prevention priorities; for example, The Surgeon General's Call to Action to Prevent Suicide 1999 (USPHS, 1999).
- Specified national strategy aims, goals, and measurable objectives integrated into a conceptual framework for suicide prevention
- Appropriate and evaluable activities for practitioners, policy makers, service providers, communities, families, agencies, and other partners
- A data collection and evaluation system to track information on suicide prevention and benchmarks for national strategy progress

## About the Goals and Objectives for Action

The Goals and Objectives for Action represents a synthesis of perspectives from researchers and scientists, practitioners, leaders of nongovernmental organizations and groups, Federal agencies, survivors, and community leaders. Because Goals and Objectives for Action is meant to be useful for applications outside the tightly controlled research environment, it builds on and extrapolates from the limited realm of scientific evidence in suicide prevention. While goals and objectives must be consistent with available scientific evidence and support the expansion of the scientific knowledge base, they are also intended for use in other environments: public policy and community action.

Goals and objectives are among many elements needed for a national strategy, not the entire strategy. The blend of evidence represented in the Goals and Objectives for Action helps guide an informed selection of activities for suicide prevention across the spectrum of the nation. The national dialogue to determine specific activities to accomplish each objective will be an extension of the consensus reached on these higher order goals and objectives. In that subsequent step, responsibility and accountability for carrying out activities will be accorded in the details of how each activity should be accomplished, by whom, and with what resources.

Development of specific activities provides the opportunity to address the particular needs of subgroups at high risk for suicide and particular cultural/ethnic/social contexts for implementation. For instance, the objective to "increase the proportion of family, youth, and community service organizations and providers with evidence based suicide prevention programs" can be achieved by different prevention activities appropriate for younger African-American males, the elderly, gay and lesbian youth, persons with major mental illnesses, or American Indians and Alaskan Natives.

Several broad themes for the National Strategy for Suicide Prevention are interwoven throughout the specific goals and objectives in this volume. These themes are valuable considerations as groups and individuals across the country move forward in designing and strengthening suicide prevention activities. The major themes are:

- Draw attention to a wide range of actions so that specific activities can be developed to fit the resources and areas of interest of people in everyday community life as well as professionals, groups, and public agencies. As the eighth leading cause (see Figure 1) of death among Americans, suicide affects families and communities everywhere across the Nation. Suicide prevention is everyone's business.
- Seek to integrate suicide prevention into existing health, mental health, substance abuse, education, and human services activities. Settings that provide related services, such as schools, workplaces, clinics, medical offices, correctional and detention centers, eldercare facilities, faith-based institutions, and community centers are all important venues for seamless suicide prevention activities.
- Guide the development of activities that will be tailored to the cultural contexts in which they are offered. While universal interventions are applicable without regard to risk status, universal does not mean that one size fits all. The cultural and developmental appropriateness of suicide prevention activities derived from these goals and objectives is a vital design and implementation criteria.
- Seek to eliminate disparities that erode suicide prevention activities. This is an important commitment in the National Strategy. Health care disparities are attributable to differences such as race or ethnicity, gender, education or income, disability, age, stigma, sexual orientation, or geographic location.
- Emphasize early interventions to reduce risk factors for suicide and promote protective factors. As important as it is to recognize and help suicidal individuals, progress depends on measures that address problems early and promote strengths so that fewer people become suicidal.
- Seek to build the Nation's capacity to conduct integrated activities to reduce suicidal behaviors and prevent suicide. Capacity building will ensure the availability of the resources, experience, skills, training, collaboration, evaluation, and monitoring necessary for success.

FIGURE 1: Suicide Among Leading Causes of Deaths by Age Group - 1998

Moving forward with these Goals and Objectives for Action can bring suicide prevention into the forefront of the Nation's public commitment to health and well-being. Working together in a coordinated and systematic way towards appropriate activities for each objective will lead to measurable progress.