# Appendix C Suicide prevention efforts in process of evaluation

## Examples of Research Efforts That May Yield Information Important to Suicide Prevention Efforts

Preventive efforts to reduce suicide should be grounded in research that provides information about modifiable risk and protective factors, as well as about appropriate target populations on which to focus prevention efforts (see The Public Health Approach as Applied to Suicide, Introduction). Once these are identified, prevention programs must be carefully tested to determine if they are safe, truly effective, and worth the considerable cost and effort needed to implement and sustain them.

Included in this appendix are examples of approaches for delivering preventive interventions aimed at target populations and/or particular settings. In the absence of clear evidence demonstrating that such approaches are effective, ongoing studies are highlighted to show where existing efforts are currently being tested, or approaches which could be evaluated with regard to their potential to reduce suicide. Because completed suicide is a relatively rare event, many programs will be limited to proving effectiveness in reducing suicide attempts and serious suicide ideation, reducing risk factors strongly associated with suicide, or strengthening protective factors.

### Preventing Youth Depression and Violence

Suicide is difficult to predict, but it does not usually "come out of the blue." Many of the factors that put youth at risk for suicide are understood, specifically mental disorders, substance abuse, prior suicide attempt, sexual abuse, impulsive and aggressive behavior, and access to a firearm (USPHS, 1999). Logically, reducing such risk factors should also reduce risk for suicide. While there are effective treatments for many of the risk factors of suicide, including depression Findling et al., 1999; Lewinsohn & Clarke, 1999, and a growing number of ways to prevent violence and to prevent and treat substance use (USPHS, 2001), the long- term outcome of these interventions in reducing suicide is not yet known.

Prior research suggests that suicidal youth are not likely to self-refer or seek help from school staff, nor do knowledgeable peers request adult help (Kalafat & Elias, 1995). This suggests that in the absence of effective ways to improve self-or peer-referral, schools would need to screen for youth at risk, and that school staff need to be trained to be aware of the warning signs for suicidal youth, and have a plan of action for helping youth at risk. The U.S. Department of Education recently issued Early warning, timely response: A guide to safe schools which offers researchbased practices designed to assist school communities in early identification of these warning signs and in developing prevention, intervention and crisis response plans (http://www.ed.gov/offices/OSERS/OSEP/earlywrn.html). Perhaps the greatest challenge for school-based suicide prevention efforts is monitoring and evaluation. A monitoring system has been successfully used by the Dade County Public Schools to assess the prevalence of suicidal behavior, identify the grade level and school classification of those youth most at risk, as well as assess progress of prevention efforts (Zenere & Lazarus, 1997). Screening approaches should be carefully considered with regard to their costs and benefits, such as the problem of over-identifying youth in need of services, lack of adequate and timely referrals, or inadvertently further stigmatizing youth at risk.

Many of the established treatments known to reduce mental and substance use disorders have been tested on youth who typically have come to the attention of care providers (parents, teachers, pediatricians). Because mental disorders and substance use disorders are under-detected and under-treated in youth U.S. Department of Health and Human Services, 1999; http://www.sg.gov/library/mentalhealth/home.html, another approach to prevention has been the use of school-based screening to identify youth at risk. At least two screening approaches are currently being investigated. One approach identifies youth at risk for dropping out of school through poor attendance and failing grades, further evaluates those youth, and then provides various types of interventions to reduce the potential for suicide and substance use (Thompson & Eggert, 1999). To date, there is no strong evidence that this approach reduces suicidality, but it has been shown to increase adolescents' sense of personal control, which may have other long-term beneficial effects. In another school-based approach, brief screening instruments are used to identify youths with depressive symptoms and/or suicidal thoughts. They are then evaluated in a more thorough manner and referred to appropriate treatment (Shaffer & Craft, 1999). The effectiveness of this approach has yet to be evaluated. While such screening efforts are more likely to detect youth at risk, they are not precise in their ability to detect only those at risk for suicide. Because of the likelihood of identifying youth with multiple problems, including those not necessarily at risk for suicide, such screening efforts can quickly burden a limited referral or service system. The hazards of labeling and not treating youth detected in such screening efforts must also be considered.

Another approach being promoted to identify at-risk youth who are not yet in treatment is gatekeeper training, involving the education of adults who regularly come in contact with suicidal youth in schools and the community. Some efforts also attempt to train youth so that they can refer other youth at risk to sources of help. The Centers for Disease Control and Prevention (CDC) has described a range of gatekeeper training approaches O'Carroll et al., 1992; http://www.cdc.gov/ncipc/pub-res/youthsui.htm. Although some evidence suggests increased knowledge and improved attitudes toward helping suicidal youth following gatekeeper training programs, none has been systematically evaluated to determine if more youth at risk are receiving treatment as a result of these programs or if the programs are preventing suicidal behavior.

Universal interventions encompass a broader health-promotion approach. Such interventions are applied to all youth and typically focus on promoting protective factors or halting the development or progression of risk factors. These efforts are applied across home, school, and peer contexts.

Successful universal interventions commonly feature efforts to build one's assets in social, problem solving, and other skills. Many initiated early in a child's life (e.g., improving early parent-child relationships, enhancing problem solving skills; increasing adaptive social behavior) have been shown effective in reducing aggression and early substance use e.g., see Catalano et al., 1998; for a review, Olds et al., 1998 Although these programs modify risk and protective factors for suicide, they have not been evaluated specifically for suicide as an outcome in adolescence or young adulthood.

The Surgeon General recently reviewed the effectiveness of violence prevention programs (USPHS, 2001), providing a comprehensive list of model programs (http://www.surgeongeneral.gov/library/youthviolence/report.html).

Safe Schools/Healthy Students, a collaborative effort of the U.S. Departments of Education, Justice, and Health and Human Services is currently funding 77 school-based violence prevention programs across the U.S. that offer opportunities to examine aspects of suicidal behavior in this population (http://www.samhsa.gov/centers/cmhs/cmhs.html). Programs with the goals of promoting healthy development, fostering resilience, and preventing violence and suicidal ideation and behavior have been planned and implemented. Data collection is ongoing and promises to yield important information about the effectiveness of the application of evidence-based practices on a large scale.

While a school setting can be considered a focus for a type of community- based prevention, other prevention approaches have considered geographic areas, such as neighborhoods. Preventive interventions for these contexts include building community assets or "collective efficacy" (Sampson, Raudenbush, & Earls, 1997). Again, whether increased collective efficacy is associated with lower suicidality has yet to be demonstrated. The U.S. Air Force approach to reducing suicide can also be considered a type of community-based intervention for adults in a work setting (see below). Additionally, some universal "policy" interventions suggest that broad-based environmental changes can have an impact on suicide rates (See the example under Individuals with Substance Use Disorders).

### Improving Follow-Up Treatment From Emergency Departments

Because the vast majority of persons do not seek follow-up treatment after attempting suicide (Piacentini et al., 1995), one approach being taken to reduce repeat attempts is to refer individuals to treatment after they have been seen in the emergency department (ED). Since adolescents and young adults are more likely to make nonfatal suicide attempts, a number of studies have focused on these subgroups. One study compared standard care to an intervention in which emergency department staff were taught to recognize the seriousness of suicide attempts, to reinforce the importance of outpatient treatment and to provide for an ED-based initial family education/therapy session. When compared to standard care, this enhanced ED intervention was shown to increase treatment attendance and decrease depression among adolescent Latino suicide attempters. (Rotheram-Borus et al., 2000). However, the sample size was too small to determine whether the intervention had an effect on the number of future suicide attempts. Another study currently being conducted is testing the effectiveness of a cognitive-behavioral therapy intervention implemented immediately after patients have been evaluated in an ED following a suicide attempt (see grant by Aaron Beck; http://www.nimh.nih.gov/research/suiabs.cfm). The targets of the intervention are modifiable risk factors such as substance abuse, depression, hopelessness, and suicidal ideation, which are addressed through problem-solving strategies, utilization of social support, and increasing compliance with adjunctive medical, substance abuse, psychiatric and social interventions.

### Primary Care Interventions for Depressed Elders

Multiple studies have found that elderly are much more likely to have contact with primary care doctors than mental health specialists in the weeks preceeding their death. Follow-back studies have also shown that the most common psychiatric disorder among elderly persons who have died by suicide is a single episode of non-psychotic, unipolar major depression without comorbid illness (Conwell et al., 2001). Because this is the most treatable type of depression, a logical approach to prevention that has been recommended is to improve the screening and treatment of depression conducted in primary care practices. Improvement could come about with the addition of screening measures, assistants dedicated to the treatment of depression and other mental health issues, or through better prescribing practices. A controlled study, PROSPECT (Prevention of Suicide in Primary Care Elderly Collaborative Trial), is currently testing the effectiveness of using Health Specialists (HS) to collaborate with physicians helping them recognize depression, offer timely and appropriately targeted treatment recommendations, and encourage patients to adhere to treatment. In addition, procedures are implemented to educate patients, families and physicians on depression and suicidal ideation (Bruce & Pearson, 1999).

### Prison/Jail Suicide

Suicide is one of the leading causes of death in our Nation's jails (Bureau of Justice Statistics, 1995). However, very little research or evaluation has been conducted on the success of suicide prevention programs implemented in jail or prison settings. Although no research directly supports any particular prevention approach in jails, guidelines for suicide prevention in jails have been implemented in some settings. Often programs are multidimensional in nature, recommending steps such as adequate mental health treatment, staff training in suicide prevention, intake screening/assessment, increasing communication in detention settings, changes in housing practices, changes in level of supervision/observation, direct intervention after suicide attempts, and adequate reporting and follow- up (Hayes, 1999). Some States have implemented State-wide jail suicide prevention programs. Of these, New York and Texas have seen drops in the rate of jail suicide since the programs were implemented. The American Correctional Association, the National Commission on Correctional Health Care, the National Juvenile Detention Association, and other national organizations have developed guidelines for suicide prevention. However, the effect of these guidelines has not been studied. In addition, Lindsay Hayes has created a comprehensive suicide prevention plan for both adult and child detention facilities that has yet to be evaluated (Hayes, 1999).

## Special Populations at Risk

### American Indians and Alaska Natives

As illustrated in Figure 4, American Indians and Alaska Natives (AIAN) have a 50 percent higher rate of suicide than the general U.S. population, with young males having the highest risk (Indian Health Service, 1997). The most common risk factors for suicide among young male AIANs is alcohol and substance use, and depression. However, there are dramatic differences in suicide rates across tribes. Many tribes, in partnership with the Indian Health Service (IHS) and other government agencies, have designed and implemented programs intended to address suicide prevention and intervention for suicide and related problems (Middlebrook et al., 2001). Prevention efforts include reducing risk behaviors (alcohol and substance use) and promoting protective factors ( increasing employment opportunities and promoting positive and encouraging attitudes among adults toward AIAN youth). Unfortunately, too few descriptions and analyses of these efforts have been published, and little is known about their effectiveness (see Middlebrook et al., 2001 for a review).

### Gay, Lesbian, and Bisexual Youth

Several State and national studies have reported that high school students who report same-sex sexual behavior or self-identify as gay, lesbian, or bisexual (GLB) have higher rates of suicidal thoughts and attempts in the past year compared to youth who report exclusively heterosexual sexual behavior or self-identify as heterosexual in orientation (McDaniel & Purcell, 2001). Experts do not agree completely about the best way to measure reports of adolescent suicide attempts, or sexual orientation, so the data are subject to question. But they do agree that efforts should focus on how to help GLB youth grow up to be healthy and successful despite the obstacles that they face. Because school-based programs limited to suicide awareness have not proven effective for youth in general, and in some cases have led youth to consider suicide as a normal response to stress or have caused increased distress in vulnerable youth (Vieland et al., 1991), there is reason to belive that they may not be helpful for GLB youth either. Issues of stigma, labeling, privacy, and appropriateness of referrals for youth needing services must be considered to ensure that prevention programs for sexual minority populations are safe and effective.

### Individuals With Borderline Personality Disorder

Three to nine percent of those diagnosed with Borderline Personality Disorder (BPD) commit suicide, a rate comparable to that for people diagnosed with mood disorders and schizophrenia (Tanney, 2000). Recurrent suicide attempts, self-injury, and impulsive aggression are often associated with BPD and often result in expensive emergency and inpatient treatment. To date, approaches to the prevention of suicidal behavior among individuals with BPD have focused on treatment to reduce self-injurious behavior with and without intent to die, including certain types of psychotherapy and pharmacotherapy. One psychosocial treatment - dialectical behavior therapy (DBT), a cognitive-behavioral treatment - has been shown to significantly decrease self-injurious behaviors in BPD (Koerner & Linehan, 2000). Although DBT has become increasingly popular as the treatment of choice for suicidal patients with BPD, no replication studies have been done other than those conducted by the developer. One study is evaluating DBT and pharmacological approaches aimed at reducing selfinjurious behavior in individuals with BPD (see grant by Barbara Stanley, http://www.nimh.nih.gov/research/suiabs.cfm).

### Individuals With Schizophrenia

The risk for suicide among individuals with schizophrenia is comparable to the risk for individuals with mood disorder, substance abuse, and BPD. In individuals with schizophrenia, the risk is particularly heightened during the early stages of the illness, and has been found to increase soon after inpatient discharge Caldwell & Gottesman, 1990; Fenton, 2000. This suggests that adequate aftercare treatments may reduce risk during this phase of disease management. Other approaches to reducing suicide risk among individuals with schizophrenia include investigations of medications that target the key symptoms of the disorder. In industry sponsored treatment trials, one of the new atypical anti-psychotic medications was observed to have the possible effect of reducing suicidal behavior in persons with schizophrenia. To confirm these findings, the International Clozaril/Leponex Suicide Prevention Trial will compare clozapine and olanzapine in 900 patients with schizophrenia and a history of suicidality (Meltzer, 1999). If these findings indicate that clozapine is effective in reducing suicidality, the makers of the drug clozapine plan to seek FDA approval for this use.

### Individuals With Substance Use Disorders

Individuals with substance use disorders, including alcoholism, are at increased risk for suicide. Follow-back studies of suicide decedents have shown that 15-56 percent of individuals had diagnoses of alcoholism and/or other substance use and dependence, a rate much higher than that in the population (Murphy, 2000). Alcohol and substance abuse problems contribute to suicidal behavior in several ways. In addition to increasing the risk of suicide directly through lowered inhibitions, people who abuse substances or alcohol also tend to have other risk factors such as depression and social and financial problems. Substance use and abuse are also common among persons prone to be impulsive, and among persons who engage in many types of high risk behaviors that result in self-harm. Fortunately, there are a number of effective prevention efforts that reduce risk for substance abuse in youth, and there are effective treatments for alcohol and substance use problems. While a number of treatments have been found to be effective for the treatment of substance abuse National Institutes of Drug Abuse, 1999; http://www.nida.nih.gov/podat/podatindex.html and alcoholism National Institute on Alcohol Abuse and Alcoholism, 2000; http://silk.nih.gov/silk/niaaa1/publication/aa49.htm, few have measured concurrent effects of treatment on rates of suicide or suicide attempts. Currently, some studies are looking at suicidal behavior among individuals who are abusing substances and are trying to treat substance use, abuse and dependence along with other comorbid psychiatric problems, as well as dealing with stressful life events (see Emergency Departments above). Some alcohol policies may be effective in reducing suicide deaths. For example, an assessment of minimum legal drinking age (MLDA) found that between 1970 and 1990, the suicide rate of 18- to 20-year-old youths living in States with an 18-year MLDA was 8 percent higher than the suicide rate among 18- to 20-year-old youths in States with a 21-year MLDA (Birckmayer & Hemenway, 1999).

### Individuals With Mood Disorders

Mood disorders are very common among individuals who commit suicide, with 36-70 percent of individuals having a mood disorder at the time of death Barraclough et al. 1974; Foster et al., 1999; Henriksson et al., 1993; Rich, Young, & Fowler, 1986. A number of long-term followup studies of individuals with bipolar disorder found that those who remain on lithium maintenance treatment have a lower risk of suicide than individuals who do not remain in treatment or are non-responsive to lithium (Jamison, 2000). A study in progress is testing whether lithium can prevent suicide attempts among individuals with bipolar disorder who have previously attempted suicide (see grant by Maria Oquendo, http://www.nimh.nih.gov/research/suiabs.cfm). The large, multisite Systematic Treatment Enhancement Program for Bipolar Disorder (STEPBD) study will track the frequency of suicidal behavior and treatment approaches used to minimize suicidal behavior (http://www.stepbd.org/). Suicide prevention approaches in STEP-BD focus on reducing inclination and minimizing opportunity through medication, psychosocial, and environmental interventions.

With regard to individuals with major depression, retrospective data indicate that many who are at risk for suicide often receive inadequate treatment (Oquendo et al., 1999). The Swedish Island of Gotland study is an uncontrolled study that has inspired efforts to increase primary care providers' abilities to detect and treat depression, and in turn reduce suicide (Rutz et al., 1989). An educational program for all general practitioners on the island to improve recognition and treatment for depression, the program was associated with more appropriate antidepressant medication prescriptions and fewer inpatient hospitalizations of depressed individuals. The island had fewer adult female suicides in the several years following the intervention (Rutz, 2001). While these results suggest that some suicide deaths may be prevented through improving the diagnosis and ongoing treatment of depression, possibly through the education of providers and the public about depression treatment, controlled studies are needed to determine the effectiveness of these approaches to reduce suicide, particularly among males.

### Populations That Need Further Attention

White males aged 24-55 constitute the greatest numbers of suicide deaths in the U.S., yet this subgroup of individuals is the least likely to have sought mental health treatment prior to death (Pirkis & Burgess, 1998). Currently there are almost no prevention approaches aimed specifically at preventing suicide among males who do not seek mental health treatment. One approach which shows promise is the prevention strategy used by the Air Force Centers for Disease Control and Prevention, 1999; http://www.cdc.gov/epo/mmwr/preview/mmwrhtml/mm4846a1.htm. This strategy is a multi-faceted approach to suicide prevention that intervened at a community-wide level. Interventions included widespread and repeated suicide awareness and prevention training, gatekeeper training, screening questionnaires, changes in mental health confidentiality policy, and messages from the Air Force Chief of Staff to change community attitudes about seeking and providing help. Surveillance results suggest that the prevention program has been effective in reducing suicide among Air Force personnel, in both majority and minority populations. Because this effort was not experimentally controlled, however, it is not known if certain aspects, or all approaches combined, were effective. Nevertheless, this intervention demonstrates the potential for suicide prevention among late adolescent and adult males in the U.S. through a combination of universal and targeted interventions.

## Summary and Future Prospects

Rates of suicide and suicidal behavior and their risk factors vary across age, gender and ethnic groups. The broad array of prevention strategies described in this appendix reflect the variation in risk factors for different subgroups, as well as the different types of disorders where suicide risk is increased. Testing interventions in different settings are ways to study these diverse risk groups. While the broad range of prevention approaches may seem unsystematic, at the same time it suggests many opportunities for individuals, organizations, and communities to consider who is at most risk for suicide and what are the strategies consistent with our understanding of protective and risk factors to reduce suicide in their communities.

If the costs of this behavior are so great, why is there so little information about what is effective in preventing suicide, suicidal behavior, and suicidal thinking? One reason for the limited number of tested programs is concern among some researchers and academic institutions about possible increased liability when conducting research with individuals at risk for suicide. Many researchers prefer to study problems that do not carry such legal and ethical responsibilities. Efforts are underway to increase the number of federally supported research efforts in this area by providing researchers with guidance and tools to design safe and ethical studies to test approaches to reducing suicidal behaviors (see http://www.nimh.nih.gov/research/highrisksuicide.cfm). In addition, suicide deaths, and even suicidal behaviors, are relatively rare events, making it difficult for researchers to determine if a prevention program was effective, unless administered to a very large population over multiple years. Thus, suicide prevention research requires large numbers of participants and can be very expensive. Nevertheless, because "suicide prevention is everyone's business," communities and organizations can learn more about persons at risk for suicide, consider the financial and social costs of suicide and its risk factors, and work to implement and evaluate prevention efforts appropriate for their communities.