# Appendices

Appendix A NSSP Goals and Objectives for Action: Summary List

Appendix B Evaluation of Suicide Prevention Programs

Appendix C Suicide prevention efforts in process of evaluation

Appendix D NSSP Federal Steering Group

Appendix E