# Preface

The NCBI Style Guide will help you communicate your thoughts effectively by providing advice on guides to style, examples of common word forms at NCBI, and helpful grammar and language tips.