# Acronyms and Abbreviations

ACC: American College of Cardiology
AHA: American Heart Association
AIDS: Acquired immune deficiency syndrome
AVID: Antiarrhythmics Versus Implantable Defibrillators trial
CABG: Coronary artery bypass graft
CABG-PATCH: Coronary Artery Bypass Graft Patch trial
CASH: Cardiac Arrest Study Hamburg trial
CDRH: Center for Devices and Radiological Health
CIDS: Canadian Implantable Defibrillator Study
CMS: Centers for Medicare & Medicaid Services
CRT: Cardiac resynchronization therapy
DEFINITE: Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial
DINAMIT: Defibrillator in Acute Myocardial Infarction Trial
EF: Ejection fraction
EP: Electrophysiology
FDA: U.S. Food and Drug Administration
HRS: Heart Rhythm Society
ICD: Implantable cardioverter defibrillator
ICDM: Ischemic dilated cardiomyopathy
ISBA: International Society for Bayesian Analysis
LVEF: Left ventricular ejection fraction
MADIT-I: Multicenter Automatic Defibrillator Implantation Trial-I
MADIT-II: Multicenter Automatic Defibrillator Implantation Trial-II
MCMC: Markov chain Monte Carlo
MI: Myocardial infarction
MUSTT: Multicenter Unsustained Tachycardiac Trial
NIDCM: Non-ischemic dilated cardiomyopathy
NYHA: New York Heart Association
PTCA: Percutaneous transluminal coronary angioplasty
RCT: Randomized controlled trial
SBP: Systolic blood pressure
SCD: Sudden cardiac death
SCD-HeFT: Sudden Cardiac Death in Heart Failure Trial
VF: Ventricular fibrillation
VT: Ventricular tachycardia