# References

1 U.S. Food and Drug Adminstration Center for Devices and Radiological Health. Guidance for the Use of Bayesian Statistics in Medical Device Clinical Trials – Draft Guidance for Industry and FDA Staff. 2006. May. 23. Accessed 26 September 2008. Available at: www.fda.gov/cdrh/osb/guidance/1601.html.
2 SAMSI Subgroups Analysis Working Group. Proceedings of meeting held July 13–26, 2006. Accessed 30 September 2008. Available at: www.samsi.info/200506/multiplicity/workinggroup/sa/index.html.
3 Spiegelhalter DJ, Abrams KR, Myles JP. Bayesian approaches to clinical trials and health-care evaluation. New York. Wiley. 2004.
4 Spiegelhalter DJ, Myles JP, Jones DR, et al. Bayesian methods in health technology assessment: a review. Health Technol Assess. 2000;4(38):1-130. [pmid: 11134920].
5 International Society for Bayesian Analysis. Bayesian Resources. Accessed 30 September 2008. Available at: www.bayesian.org/resources/index.html.
6 Fisher LD. Comments on Bayesian and frequentist analysis and interpretation of clinical trials. Control Clin Trials. 1996;17(5):423-434. [pmid: 8932975].
7 Gennari A, Amadori D, De Lena M, et al. Lack of benefit of maintenance paclitaxel in first-line chemotherapy in metastatic breast cancer. J Clin Oncol. 2006;24(24):3912-3918. [pmid: 16921042].
8 Tyson JE, Kennedy KA, Lucke JF, et al. Dilemmas initiating enteral feedings in high risk infants: how can they be resolved?. Semin Perinatol. 2007;31(2):61-73. [pmid: 17462490].
9 Brophy JM, Joseph L. Medical decision making with incomplete evidence--choosing a platelet glycoprotein IIbIIIa receptor inhibitor for percutaneous coronary interventions. Med Decis Making. 2005;25(2):222-228. [pmid: 15800306].
10 Kpozehouen A, Alioum A, Anglaret X, et al. Use of a Bayesian approach to decide when to stop a therapeutic trial: the case of a chemoprophylaxis trial in human immunodeficiency virus infection. Am J Epidemiol. 2005;161(6):595-603. [pmid: 15746476].
11 Schmid CH, Cappelleri JC, Lau J. Bayesian methods to improve sample size approximations. Methods Enzymol. 2004;383:406-427. [pmid: 15063660].
12 Wang H, Chow S-C, Chen M. A Bayesian approach on sample size calculation for comparing means. J Biopharm Stat. 2005;15(5):799-807. [pmid: 16078386].
13 Lewis RJ, Lipsky AM, Berry DA. Bayesian decision-theoretic group sequential clinical trial design based on a quadratic loss function: a frequentist evaluation. Clin Trials. 2007;4(1):5-14. [pmid: 17327241].
14 Dmitrienko A, Wang M-D. Bayesian predictive approach to interim monitoring in clinical trials. Stat Med. 2006;25(13):2178-2195. [pmid: 16007570].
15 Freedman LS, Spiegelhalter DJ. Application of Bayesian statistics to decision making during a clinical trial. Stat Med. 1992;11(1):23-35. [pmid: 1557573].
16 Freedman LS, Spiegelhalter DJ. Comparison of Bayesian with group sequential methods for monitoring clinical trials. Control Clin Trials. 1989;10(4):357-367. [pmid: 2691203].
17 Emerson SS, Kittelson JM, Gillen DL. Bayesian evaluation of group sequential clinical trial designs. Stat Med. 2007;26(7):1431-1449. [pmid: 17066402].
18 Dignam JJ, Bryant J, Wieand HS, et al. Early stopping of a clinical trial when there is evidence of no treatment benefit: protocol B-14 of the National Surgical Adjuvant Breast and Bowel Project. Control Clin Trials. 1998;19(6):575-588. [pmid: 9875837].
19 George SL, Li C, Berry DA, et al. Stopping a clinical trial early: frequentist and Bayesian approaches applied to a CALGB trial in non-small-cell lung cancer. Stat Med. 1994;13(13–14):1313-1327. [pmid: 7973212].
20 Berry DA, Wolff MC, Sack D. Decision making during a phase III randomized controlled trial. Control Clin Trials. 1994;15(5):360-378. [pmid: 8001357].
21 Thall PF, Wathen JK. Practical Bayesian adaptive randomisation in clinical trials. Eur J Cancer. 2007;43(5):859-866. [pmid: 17306975].
22 Avins AL. Can unequal be more fair? Ethics, subject allocation, and randomised clinical trials. J Med Ethics. 1998;24(6):401-408. [pmid: 9873981].
23 Sheingold SH. Can Bayesian methods make data and analyses more relevant to decision makers? A perspective from Medicare. Int J Technol Assess Health Care. 2001;17(1):114-122. [pmid: 11329838].
24 Winkler RL. Why Bayesian analysis hasn't caught on in healthcare decision making. Int J Technol Assess Health Care. 2001;17(1):56-66. [pmid: 11329845].
25 Rothwell PM. Treating individuals 2. Subgroup analysis in randomised controlled trials: importance, indications, and interpretation. Lancet. 2005;365(9454):176-186. [pmid: 15639301].
26 Pocock SJ, Assmann SE, Enos LE, et al. Subgroup analysis, covariate adjustment and baseline comparisons in clinical trial reporting: current practice and problems. Stat Med. 2002;21(19):2917-2930. [pmid: 12325108].
27 Brookes ST, Whitley E, Peters TJ, et al. Subgroup analyses in randomised controlled trials: quantifying the risks of false-positives and false-negatives. Health Technol Assess. 2001;5(33):1-56. [pmid: 11701102].
28 The European Agency for the Evaluation of Medicinal Products Committee for Proprietary Medicinal Products. Points to Consider on Multiplicity Issues in Clinical Trials. 2002. Accessed 28 September 2008. Available at: www.samsi.info/200506/multiplicity/workinggroup/sa/multiplicity.points.EU2002.pdf.
29 Moher D, Schulz KF, Altman DG. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomised trials. Lancet. 2001;357(9263):1191-1194. [pmid: 11323066].
30 Jones B, Teather D, Wang J, et al. A comparison of various estimators of a treatment difference for a multi-centre clinical trial. Stat Med. 1998;17(15–16):1767-1777. discussion 1799–800. [pmid: 9749446].
31 Simon R. Bayesian subset analysis: application to studying treatment-by-gender interactions. Stat Med. 2002;21(19):2909-2916. [pmid: 12325107].
32 Goodman SN, Sladky JT. A Bayesian approach to randomized controlled trials in children utilizing information from adults: the case of Guillain-Barre syndrome. Clin Trials. 2005;2(4):305-310. discussion 364–78. [pmid: 16281429].
33 Senn S. Trying to be precise about vagueness. Stat Med. 2007;26(7):1417-1430. [pmid: 16906552].
34 Spiegelhalter DJ, Myles JP, Jones DR, et al. Methods in health service research. An introduction to Bayesian methods in health technology assessment. BMJ. 1999;319(7208):508-512. [pmid: 10454409].
35 Bloom BS, de Pouvourville N, Libert S. Classic or Bayesian research design and analysis. Does it make a difference?. Int J Technol Assess Health Care. 2002;18(1):120-126. [pmid: 11987435].
36 Hahn S, Whitehead A. An illustration of the modelling of cost and efficacy data from a clinical trial. Stat Med. 2003;22(6):1009-1024. [pmid: 12627415].
37 Heitjan DF, Li H. Bayesian estimation of cost-effectiveness: an importance-sampling approach. Health Econ. 2004;13(2):191-198. [pmid: 14737756].
38 Ades AE, Sculpher M, Sutton A, et al. Bayesian methods for evidence synthesis in cost-effectiveness analysis. Pharmacoeconomics. 2006;24(1):1-19. [pmid: 16445299].
39 Nixon RM, Thompson SG. Methods for incorporating covariate adjustment, subgroup analysis and between-centre differences into cost-effectiveness evaluations. Health Econ. 2005;14(12):1217-1229. [pmid: 15945043].
40 Vanness DJ, Kim WR. Bayesian estimation, simulation and uncertainty analysis: the cost-effectiveness of ganciclovir prophylaxis in liver transplantation. Health Econ. 2002;11(6):551-566. [pmid: 12203757].
41 Briggs AH. A Bayesian approach to stochastic cost-effectiveness analysis. Health Econ. 1999;8(3):257-261. [pmid: 10348420].
42 Briggs AH. A Bayesian approach to stochastic cost-effectiveness analysis. An illustration and application to blood pressure control in type 2 diabetes. Int J Technol Assess Health Care. 2001;17(1):69-82. [pmid: 11329846].
43 O'Hagan A, Stevens JW, Montmartin J. Inference for the cost-effectiveness acceptability curve and cost-effectiveness ratio. Pharmacoeconomics. 2000;17(4):339-349. [pmid: 10947489].
44 Harrell FE Jr, Shih YC. Using full probability models to compute probabilities of actual interest to decision makers. Int J Technol Assess Health Care. 2001;17(1):17-26. [pmid: 11329842].
45 Stevens JW, O'Hagan A. Incorporation of genuine prior information in cost-effectiveness analysis of clinical trial data. Int J Technol Assess Health Care. 2002;18(4):782-790. [pmid: 12602079].
46 American Heart Association. Heart Disease and Stroke Statistics - 2008 Update. Accessed 30 September 2008. Available at: www.americanheart.org/downloadable/heart/1200082005246HS_Stats%202008.final.pdf.
47 Bardy GH, Lee KL, Mark DB, et al. Amiodarone or an implantable cardioverter-defibrillator for congestive heart failure. [erratum appears in N Engl J Med 2005 May 19;352(20):2146]. N Engl J Med. 2005;352(3):225-237. [pmid: 15659722].
48 Hohnloser SH, Kuck KH, Dorian P, et al. Prophylactic use of an implantable cardioverter-defibrillator after acute myocardial infarction. N Engl J Med. 2004;351(24):2481-2488. [pmid: 15590950].
49 Kadish A, Dyer A, Daubert JP, et al. Prophylactic defibrillator implantation in patients with nonischemic dilated cardiomyopathy. N Engl J Med. 2004;350(21):2151-2158. [pmid: 15152060].
50 Moss AJ, Zareba W, Hall WJ, et al. Prophylactic implantation of a defibrillator in patients with myocardial infarction and reduced ejection fraction. N Engl J Med. 2002;346(12):877-883. [pmid: 11907286].
51 Kuck KH, Cappato R, Siebels J, et al. Randomized comparison of antiarrhythmic drug therapy with implantable defibrillators in patients resuscitated from cardiac arrest : the Cardiac Arrest Study Hamburg (CASH). Circulation. 2000;102(7):748-754. [pmid: 10942742].
52 Connolly SJ, Gent M, Roberts RS, et al. Canadian implantable defibrillator study (CIDS) : a randomized trial of the implantable cardioverter defibrillator against amiodarone. Circulation. 2000;101(11):1297-1302. [pmid: 10725290].
53 Buxton AE, Lee KL, Fisher JD, et al. A randomized study of the prevention of sudden death in patients with coronary artery disease. [erratum appears in N Engl J Med 2000 Apr 27;342(17):1300]. N Engl J Med. 1999;341(25):1882-1890. [pmid: 10601507].
54 The Antiarrhythmics versus Implantable Defibrillators (AVID) Investigators. A comparison of antiarrhythmic-drug therapy with implantable defibrillators in patients resuscitated from near-fatal ventricular arrhythmias. N Engl J Med. 1997;337(22):1576-1583. [pmid: 9411221].
55 Bigger JT Jr. Coronary Artery Bypass Graft (CABG) Patch Trial Investigators. Prophylactic use of implanted cardiac defibrillators in patients at high risk for ventricular arrhythmias after coronary-artery bypass graft surgery. N Engl J Med. 1997;337(22):1569-1575. [pmid: 9371853].
56 Moss AJ, Hall WJ, Cannom DS, et al. Improved survival with an implanted defibrillator in patients with coronary disease at high risk for ventricular arrhythmia. N Engl J Med. 1996;335(26):1933-1940. [pmid: 8960472].
57 Epstein AE, DiMarco JP, Ellenbogen KA, et al. ACC/AHA/HRS 2008 Guidelines for Device-Based Therapy of Cardiac Rhythm Abnormalities: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Writing Committee to Revise the ACC/AHA/NASPE 2002 Guideline Update for Implantation of Cardiac Pacemakers and Antiarrhythmia Devices): developed in collaboration with the American Association for Thoracic Surgery and Society of Thoracic Surgeons. Circulation. 2008;117(21):e350-e408. [pmid: 18483207].
58 American College of Cardiology, Heart Rhythm Society. ICD Registry. Accessed 30 September 2008. Available at: www.vertexcommunication.com/acc/ICDJune.jpg.
59 Anonymous. National Cardiovascular Data Registry Elements and Definitions - ICD Registry. Accessed 30 September 2008. Available at: http://www.ncdr.com/WebNCDR/ICD/ELEMENTS.ASPX.
60 Al-Khatib SM, Sanders GD, Mark DB, et al. Implantable cardioverter defibrillators and cardiac resynchronization therapy in patients with left ventricular dysfunction: randomized trial evidence through 2004. Am Heart J. 2005;149(6):1020-1034. [pmid: 15976783].
61 Austin PC, Brunner LJ, Hux JE. Bayeswatch: an overview of Bayesian statistics. J Eval Clin Pract. 2002;8(2):277-286. [pmid: 12060417].
62 Berry DA. A case for Bayesianism in clinical trials. Stat Med. 1993;12(15–16):1377-1393. discussion 1395–404. [pmid: 8248653].
63 Berry DA. Benefits and risks of screening mammography for women in their forties: a statistical appraisal. J Natl Cancer Inst. 1998;90(19):1431-1439. [pmid: 9776408].
64 Berry DA. Bayesian clinical trials. Nat Rev Drug Discov. 2006;5(1):27-36. [pmid: 16485344].
65 Brown BW, Herson J, Atkinson EN, et al. Projection from previous studies: a Bayesian and frequentist compromise. Control Clin Trials. 1987;8(1):29-44. [pmid: 3568694].
66 Diamond GA, Kaul S. Prior convictions: Bayesian approaches to the analysis and interpretation of clinical megatrials. J Am Coll Cardiol. 2004;43(11):1929-1939. [pmid: 15172393].
67 Fisher LD. Self-designing clinical trials. Stat Med. 1998;17(14):1551-1562. [pmid: 9699229].
68 Gould AL. Bayesian analysis of multicentre trial outcomes. Stat Methods Med Res. 2005;14(3):249-280. [pmid: 15969303].
69 Greenhouse JB, Wasserman L. Robust Bayesian methods for monitoring clinical trials. Stat Med. 1995;14(12):1379-1391. [pmid: 7569495].
70 Grieve A, Senn S. Estimating treatment effects in clinical crossover trials. J Biopharm Stat. 1998;8(2):191-233. discussion 235–47. [pmid: 9598420].
71 Howard G. Nonconventional clinical trial designs: approaches to provide more precise estimates of treatment effects with a smaller sample size, but at a cost. Stroke. 2007;38(2 Suppl):804-808. [pmid: 17261743].
72 Kaul S, Diamond GA. Making sense of noninferiority: a clinical and statistical perspective on its application to cardiovascular clinical trials. Prog Cardiovasc Dis. 2007;49(4):284-299. [pmid: 17185116].
73 Lilford RJ, Thornton JG, Braunholtz D. Clinical trials and rare diseases: a way out of a conundrum. BMJ. 1995;311(7020):1621-1625. [pmid: 8555809].
74 Localio AR, Berlin JA, Have TRT. Longitudinal and repeated cross-sectional cluster-randomization designs using mixed effects regression for binary outcomes: bias and coverage of frequentist and Bayesian methods. Stat Med. 2006;25(16):2720-2736. [pmid: 16345043].
75 Louis TA. Introduction to Bayesian methods II: fundamental concepts. Clin Trials. 2005;2(4):291-294. discussion 301–4. [pmid: 16281427].
76 Matsuyama Y, Sakamoto J, Ohashi Y. A Bayesian hierarchical survival model for the institutional effects in a multi-centre cancer clinical trial. Stat Med. 1998;17(17):1893-1908. [pmid: 9777685].
77 Maurer W. Creative and innovative statistics in clinical research and development. Methods Inf Med. 2005;44(4):551-560. [pmid: 16342922].
78 Piantadosi S. Principles of clinical trial design. Semin Oncol. 1988;15(5):423-433. [pmid: 3051399].
79 Pocock SJ, Hughes MD. Estimation issues in clinical trials and overviews. Stat Med. 1990;9(6):657-671. [pmid: 2145623].
80 Vail A, Hornbuckle J, Spiegelhalter DJ, et al. Prospective application of Bayesian monitoring and analysis in an "open" randomized clinical trial. Stat Med. 2001;20(24):3777-3787. [pmid: 11782033].
81 Dixon DO, Simon R. Bayesian subset analysis. [erratum appears in Biometrics 1994 Mar;50(1):322]. Biometrics. 1991;47(3):871-881. [pmid: 1742443].
82 Dixon DO, Simon R. Bayesian subset analysis in a colorectal cancer clinical trial. Stat Med. 1992;11(1):13-22. [pmid: 1557569].
83 Greenland S. Bayesian perspectives for epidemiological research. II. Regression analysis. Int J Epidemiol. 2007;36(1):195-202. [pmid: 17329317].
84 Burr D, Doss H, Cooke GE, et al. A meta-analysis of studies on the association of the platelet PlA polymorphism of glycoprotein IIIa and risk of coronary heart disease. Stat Med. 2003;22(10):1741-1760. [pmid: 12720308].
85 Jones DR. Meta-analysis: weighing the evidence. Stat Med. 1995;14(2):137-149. [pmid: 7754262].
86 Lambert PC, Sutton AJ, Burton PR, et al. How vague is vague? A simulation study of the impact of the use of vague prior distributions in MCMC using WinBUGS. Stat Med. 2005;24(15):2401-2428. [pmid: 16015676].
87 Nguyen ND, Wang CY, Eisman JA, et al. On the association between statin and fracture: a Bayesian consideration. Bone. 2007;40(4):813-820. [pmid: 17178257].
88 Normand SL. Meta-analysis: formulating, evaluating, combining, and reporting. Stat Med. 1999;18(3):321-359. [pmid: 10070677].
89 Sung L, Beyene J, Hayden J, et al. A Bayesian meta-analysis of prophylactic granulocyte colony-stimulating factor and granulocyte-macrophage colony-stimulating factor in children with cancer. Am J Epidemiol. 2006;163(9):811-817. [pmid: 16554346].
90 Sutton AJ, Abrams KR. Bayesian methods in meta-analysis and evidence synthesis. Stat Methods Med Res. 2001;10(4):277-303. [pmid: 11491414].
91 Kleinbaum DG, Klein M. Survival analysis: a self-learning text. New York, NY. Springer. 2005. 2nd edition.