# Glossary of Terms

Adaptive designs: Adaptive design is a trial design that allows modifications to some aspects of the trial after its initiation without undermining the validity and integrity of the trial. The following are examples of modifications to a trial: sample size re-estimation, early stopping due to efficacy or futility, adaptive randomization, and dropping inferior treatment groups.
Baseline hazard function: The hazard function in the absence of covariates.
Bayesian analysis (or Bayesian statistics): An analysis that starts with a particular probability of an event (the prior probability) and incorporates new information to generate a revised probability (a posterior probability).
Bayesian hierarchical model: In a standard Bayesian model, the parameters are drawn from prior distributions, the parameters of which are fixed by the modeler. In a hierarchical model, these parameters are also free to vary and are themselves drawn from priors. This form of modeling is most useful for data that is composed of exchangeable groups for which the possibility is required that the parameters that describe each group might or might not be the same. The basic idea in a hierarchical model is that when you look at the likelihood function, and decide on the right priors, it may be appropriate to use priors that themselves depend on other parameters not mentioned in the likelihood. These parameters themselves will require priors, which themselves may (or may not) depend on new parameters. Eventually the process terminates when we no longer introduce new parameters.
Bayes’ theorem: Bayes' theorem relates the conditional and marginal probabilities of events A and B:
  P(A|B) = [P(B|A)P(A)]/P(B)
  where P(A) is the prior probability or marginal probability of A. It is "prior" in the sense that it does not take into account any information about B. P(A|B) is the conditional probability of A, given B. It is also called the posterior probability because it is derived from or depends upon the specified value of B. P(B|A) is the conditional probability of B given A. P(B) is the prior or marginal probability of B. Intuitively, Bayes' theorem in this form describes the way in which one's beliefs about observing 'A' are updated by having observed 'B'.
Bonferroni’s adjustment: When performing multiple statistical significance tests on the same data, the Bonferroni adjustment can be applied to make it more "difficult" for any one test to be statistically significant. For example, when reviewing multiple correlation coefficients form a correlation matrix, accepting and interpreting the correlations that are statistically significant at the conventional 0.05 level may be inappropriate, given that multiple tests are performed. Specifically, the alpha error probability of erroneously accepting the observed correlation coefficient as not-equal-to-zero when in fact (in the population) it is equal to zero may be much larger than 0.05 in this case. The Bonferroni adjustment usually is accomplished by dividing the alpha level (usually set to 0.05, 0.01, etc.) by the number of tests being performing.
Borrowing strength: This is the tendency in a Bayesian model for the posterior distributions of parameters among exchangeable units to become narrower as a result of pooling information across units.
Confidence interval: The confidence interval is an interval estimate of a population parameter. Instead of estimating the parameter by a single value, an interval likely to include the parameter is given. Thus, confidence intervals are used to indicate the reliability of an estimate. How likely the interval is to contain the parameter is determined by the confidence level or confidence coefficient. Increasing the desired confidence level will widen the confidence interval.
Cox proportional hazards model: A model for ongoing risk over time in which the risks (hazards) are proportional among subgroups, but the base hazard may vary over time.
Credible interval: The calculated interval that has a specified (subjective) probability of containing a parameter of interest (such as a regression coefficient, or hazard ratio, for example), given the observed data. For example, if one obtained a 95 percent credible interval for some parameter, say, hazard ratio, of 0.77 to 0.96, with a mode of 0.85, then we would conclude that the most likely value of hazard ratio was 0.85 and that we were 95 percent certain that the true value of hazard ratio was between 0.77 and 0.96.
Fixed-effect model: A model to generate a summary estimate of the magnitude of effect in a meta-analysis that restricts inferences to the set of studies included in the meta-analysis and assumes that a single true value underlies all of the primary study results. The assumption is that if all studies were infinitely large, they would yield identical estimates of effect; thus, observed estimates of effect differ from one another only because of random error. This model takes only within-study variation into account and not between-study variation.
Hazard ratio: The ratio of ongoing risk, between two groups being compared, of an outcome (e.g., death) – assumed to be constant over the study period; often reported in the context of survival analysis.
Informative prior: Informative priors have a stronger influence on the posterior distribution. The influence of the prior distribution on the posterior is related to the sample size of the data and the form of the prior. Generally speaking, large sample sizes are required to modify strong priors, where weak priors are overwhelmed by even relatively small sample sizes. Informative priors are typically obtained from past data.
Interaction: Statistical interaction means the effect of one independent variable(s) on the dependent variable depends on the value of another independent variable(s).
Kaplan-Meier survival curves: A plot of the Kaplan-Meier estimate of the survival function is a series of horizontal steps of declining magnitude which, when a large enough sample is taken, approaches the true survival function for that population. The value of the survival function between successive distinct sampled observations is taken to be constant.
Maximum likelihood estimation: A method of parameter estimation in which a parameter is estimated to be that value for which the data are most likely. For a fixed set of data and underlying probability model, maximum likelihood picks the value of the model parameters that make the data "more likely" than any other values of the parameters would make them. Maximum likelihood estimation gives a unique and easy way to determine solution in the case of the normal distribution and many other problems, although in very complex problems this may not be the case. If a uniform prior distribution is assumed over the parameters, the maximum likelihood estimate coincides with the most probable values thereof.
Non-informative prior: Non-informative prior distributions (a.k.a., vague, flat and diffuse) are distributions that have no population basis and play a minimal role in the posterior distribution. The idea behind the use of non-informative prior distributions is to make inferences that are not greatly affected by external information or when external information is not available. The uniform distribution is frequently used as a non-informative prior.
Posterior credible interval: A Bayesian 95 percent posterior credible interval may be interpreted in a straightforward manner as an interval that contains the parameter of interest with 95 percent probability given the observed data.
Posterior predictive survival distribution: The posterior predictive survival distribution is the survival distribution of unobserved observations (prediction) conditional on the observed data.
Posterior probability: Bayesian probability derived from the prior probability of an event and its likelihood, the latter derived from data.
Prior (or “prior probability”): The prior (or prior probability) is interpreted as a description of what is known about a variable in the absence of further evidence.
Prior distribution: The prior distribution is a key part of Bayesian inference and represents the information about an uncertain parameter Θ that is combined with the probability distribution of new data to yield the posterior distribution, which in turn is used for future inferences and decisions involving Θ.
Random-effects model: A model used to give a summary estimate of the magnitude of an effect in a meta-analysis that assumes that the studies included are a random sample of a population of studies addressing the question posed in the meta-analysis. Each study estimates a different underlying true effect, and the distribution of these effects is often assumed to be normal around a mean value. Because a random-effects model takes into account both within-study and between-study variability, the confidence interval around the point estimate is, when there is appreciable variability in results across studies, wider than it could be if a fixed-effects model were used.
Spline: The term “spline” is used to refer to a wide class of functions that are used in applications requiring data interpolation and/or smoothing.
Variance: The technical term for the statistical estimate of the variability in results.
Weibull regression model: A proportional hazards model which uses the Weibull distribution. It is a versatile distribution that can take on the characteristics of other types of distributions, based on the value of the shape parameter.