# Executive Summary

## Research Questions

What are the advantages and disadvantages of Bayesian statistical techniques in clinical trial design and analysis, and what is the potential impact of these approaches on policy-level decision-making by the Centers for Medicare & Medicaid Services (CMS)?

## Methods

We provide a basic tutorial on Bayesian statistics and the possible uses of such statistics in clinical trial design and analysis. We conducted a synthesis of existing published research focusing on how Bayesian techniques can modify inferences that affect policy-level decisionmaking. Noting that subgroup analysis is a particularly fruitful application of Bayesian methodology, and an area of particular interest to CMS, we focused our efforts there rather on the design of such trials. We used simulation studies and a case study of patient-level data from eight trials to explore Bayesian techniques in the CMS decisional context in the clinical domain of the prevention of sudden cardiac death and the use of the implantable cardioverter defibrillator (ICD). We combined knowledge gained through the literature review, simulation studies, and the case study to provide findings concerning the use of Bayesian approaches specific to the CMS context.

## Results

Our literature review summarized articles categorized into four themes: (1) the advantages and disadvantages of Bayesian techniques in clinical trial design and analysis; (2) the use of Bayesian techniques in subgroup analyses; (3) the use of Bayesian techniques in meta-analysis; and (4) the effect of using Bayesian techniques on policymaking/decisionmaking. Our simulation studies demonstrated that while single trials may be adequately powered to detect main treatment effects, they often have low power to detect treatment-covariate interactions. Furthermore, these studies demonstrated that combining data from trials improves the power to detect such treatment-covariate interactions. Our ICD case study explored the findings from our simulation studies and sought to provide evidence concerning the advantages and disadvantages of Bayesian techniques in clinical trial design and analysis. This case study led us to the following key findings:

- The analysis of the individual ICD trials found that, out of eight trials, five showed evidence of treatment effect, but there was also a lot of variation in the estimates of ICD effect across trials. Within any trial, the results were fairly robust to different model formulations. Generally there was no evidence of significant treatment-covariate interactions in the prognostic subgroups.
- Combining data from trials improves our inferences by increasing the precision of our estimates, as well as the power to detect main effects and interactions. A variety of modeling approaches allow us to combine data from different trials, but they do not necessarily lead to the same inference.
- Understanding the underlying model assumptions and limitations is important when interpreting the results from the combined analysis. For example, we observed that some models showed evidence for an interaction between treatment and age in the combined analysis. But this evidence arises from models that assume that this interaction is the same across all trials. If this assumption is regarded as unreasonable, and we consider instead a model that accounts for the variation of the interaction across trials, then the interaction between treatment and age is no longer significant.
- When considering Bayesian estimation, the role of priors should also be examined through a sensitivity analysis.
- Our analyses demonstrate that we can utilize Bayesian hierarchical models to predict survival from patients in subgroups. We found, however, that survival predictions from the analysis based on randomized trials may not be comparable to the empirical survival observed in the registry. One reason may be that patients in the registry may have different prognoses from those seen in clinical trials.
- We examined the use of patient-level data versus aggregate data as information accrues over time. Our analysis showed that the resulting inferences are not necessarily the same. The analysis of aggregate data may be more sensitive to priors.
- We note that an analysis which assesses the interactions between treatment and covariates defining the subgroups of interest may not be feasible with aggregate data.

## Conclusions

Based on our review of the literature, simulation studies, and our case study, we conclude the following concerning the use of Bayesian statistical approaches in CMS policy- and decisionmaking.

1. CMS should consider claims about differential subgroup effects only if they are accompanied by a formal statistical test for interaction.
  a. Claims about differential subgroup effects based on stratified analysis should only be considered as exploratory. These analyses are compromised by the small sample sizes and post hoc decisions regarding the number of tested subgroups.
  b. Subgroup effects observed in a specific trial should be placed into context by using a statistical model that combines information across trials and across subgroups. The random-effects/hierarchical models do both.
2. To increase the statistical power to detect those interactions that in fact exist, consider using all sources of data in order to stipulate within the statistical model which types of interaction are likely. For example, observational data and expert opinion might suggest that if an interaction is present it will take the form of decreasing ICD efficacy with increasing burden of disease
3. Base study design and decisionmaking only on those subgroup effects that are likely to be strong. The power to detect interactions is not universally high, and focusing attention on the most likely candidates will limit the number of subgroups that are analyzed, and thus limit the pernicious effects of random variation.
4. If the trial-based data are sufficient, do not directly combine trial-based data with information from other sources such as observational data and expert opinion. In this case the objective data are sufficient, and there is no need to utilize subjective information. Instead, use these other sources as informal sources of validation, and also to help design the statistical model for the trials (see below).
5. When little or no trial-based information about a subgroup is available, consider the use of other data (e.g., trial-based information from other subgroups, observational data, expert opinion) in order to specify a prior distribution. Unless special circumstances such as small patient pools are present, do not use this information to make final decisions about efficacy within the subgroups in question, but instead use this information to plan further studies. This suggests that the more controversial applications of Bayesian methodology should be reserved for those situations in which the decisionmaker has no other choice, and should, in any case, not be considered definitive.
6. Claims based on Bayesian methods should provide sensitivity analysis to the assumed priors. While for large trials the results are not sensitive to prior choices, this is not the case for small size trials. It is therefore important to demonstrate through sensitivity analyses how the choice of the prior impacts (or does not impact) the findings.

## Summary

The use of Bayesian statistical approaches has gained broader acceptance within the clinical trial community. The impact of these methods on CMS decisional contexts and policy-level decisionmaking however was uncertain. Our analyses explore the main proclaimed advantages of Bayesian statistics (namely, the use of prior information, sample size determination, borrowing strength from different trials, and sequential monitoring of trials) and provide examples of decisionmaking situations where the findings reached using these approaches both agree with and differ from findings reached using frequentist statistical techniques.

Our findings confirm that, like classical techniques, Bayesian approaches are affected by the problems of model specification (i.e., the relationship between various factors – patient, provider, intervention, and other contextual features – and the outcome of interest). In addition, Bayesian approaches can be substantially affected by the “Bayesian prior” – the representation of beliefs about the quantity of interest (e.g., relative risk of events when a new device is used vs. a conventional device). Thus, when considering using or interpreting Bayesian analyses, the focus of attention and thoughtful ex ante agreement are the specification of the model and specification of the Bayesian prior. The case study of the use of ICD therapy in the prevention of sudden cardiac death demonstrates the application of these techniques and highlights some of the practical challenges.

The use of Bayesian statistical approaches, and incorporation of our findings concerning their strengths and limitations into the CMS decisionmaking process will enable policymakers to harness the power of the available sources of clinical evidence, explore subgroup effects within a trial and across trials in a methodologically rigorous manner, assess the uncertainty in clinical trial findings, and – ideally – improve health outcomes for Medicare beneficiaries.