# Interpretation of Findings in the CMS Context

## Statement of Findings

Based on our review of the literature, simulation studies, and case study, we conclude the following concerning the use of Bayesian statistical approaches in CMS policy- and decisionmaking.

1. CMS should consider claims about differential subgroup effects only if they are accompanied by a formal statistical test for interaction. In other words, aberrant subgroup results should not be taken at face value.
  a. Claims about differential subgroup effects based on stratified analysis should only be considered as exploratory. These analyses are compromised by the small sample sizes and post hoc decisions regarding the number of tested subgroups. [Evidence: In Table 5 we noted, for example, that there was no evidence of ICD efficacy in the DEFINITE trial. However, in Table 6, using stratified analysis (and without adjustment for multiple testing) one could claim ICD efficacy in the subgroup age 75 or older, with EF less or equal to 30 percent, NYHA III and non-ischemic. However, Appendix Table A8 shows that there is no significant interactions between treatment and prognostic variables in the DEFINITE trial]
  b. Subgroup effects observed in a specific trial should be placed into context by using a statistical model that combines information across trials and across subgroups. The random-effects/hierarchical models do both. This will reduce the statistical error rates. [Evidence: In Appendix Table A7, there was some evidence for an interaction between treatment and ejection fraction in the CASH trial. However, other trials have not supported such an interaction. We formally examined this interaction across trials and subgroups with models that assessed the interaction using the combined data. Such models also did not support the interaction between treatment and ejection fraction (see Appendix Tables A14–A17 and A18–A21, using models estimated using frequentist or Bayesian methods, respectively). However, the evidence from the combined analysis has improved precision. Simulation results also show increased power to detect interactions in the combined analysis.]
2. To increase the statistical power to detect those interactions that in fact exist, consider using all sources of data in order to stipulate within the statistical model which types of interaction are likely. For example, observational data and expert opinion might suggest that if an interaction is present it will take the form of decreasing ICD efficacy with increasing burden of disease. Looking specifically for this type of interaction will increase statistical power. [Evidence: See literature review in Chapter 3.]
3. Base study design and decisionmaking only on those subgroup effects that are likely to be strong. The power to detect interactions is not universally high, and focusing attention on the most likely candidates will limit the number of subgroups that are analyzed, and thus limit the pernicious effects of random variation. [Evidence: See literature review in Chapter 3.]
4. If the trial-based data are sufficient, do not directly combine trial-based data with information from other sources such as observational data and expert opinion. Instead, use these other sources as informal sources of validation, and also to help design the statistical model for the trials (see below). [Evidence: See literature review in Chapter 3.]
5. When little or no trial-based information about a subgroup is available, consider the use of other data (e.g., trial-based information from other subgroups, observational data, expert opinion) in order to specify a prior distribution. Unless special circumstances such as small patient pools are present, do not use this information to make final decisions about efficacy within the subgroups in question, but instead use this information to plan further studies. In essence, this finding suggests that the more controversial applications of Bayesian methodology should be reserved for those situations in which the decisionmaker has no other choice, and should, in any case, not be considered definitive. [Evidence: See literature review in Chapter 3.] We also note that in situations where a trial appears aberrant, one may adopt a cross-validation approach, considering the analysis with and without the data arising from that particular trial. This would allow us to assess how influential the trial might be in the overall conclusions.
6. Claims based on Bayesian methods should provide sensitivity analysis to the assumed priors. While for large trials the results are not sensitive to prior choices, this is not the case for small size trials and therefore the sensitivity analyses to the assumed priors are needed. [Evidence: To illustrate this point, consider results shown in Appendix Figure A5(b). When only data from a single trial are considered, analysis results are more sensitive to the prior choices. However, when we increase the sample size (in this case, by combining data from trials) we reduce the sensitivity to prior choices].
7. Results from aggregate data analysis are not necessarily consistent with those obtained using patient-level data. Aggregate data analysis may ignore, for example, additional sources of variation; for example, those that explain patient-to-patient variation within a study. This is a critical point particularly in observational studies, where aggregate data can lead to confounding, and explains why CMS should continue to encourage investigators to submit their raw data to facilitate analysis. [Evidence: See the section on “Analysis of Aggregate versus Patient-level Data” in Chapter 5.]
8. Combining data from trials sequentially may allow us to conclude overall efficacy sooner. As already pointed out under item 6, above, sensitivity analysis will clarify the role of the priors for reaching such a conclusion. Although not illustrated here, a similar comment applies when analyzing data within any trial sequentially (that is, when performing interim analysis). [Evidence: See the section on “Analysis of Aggregate versus Patient-level Data” in Chapter 5.]

## Summary

Bayesian statistical approaches provide a formal method of learning from evidence as it accumulates. The potential benefits of Bayesian approaches – especially when good prior information is available have allowed the use of these techniques to become more popular within the clinical trial community. The impact of these approaches on CMS policy-level decisionmaking however is uncertain.

In this report we provide an overview of the published literature concerning the advantages and disadvantages of Bayesian techniques in clinical trial design and analysis, the use of these approaches in subgroup analysis, and their strengths in meta-analysis of the clinical information as it accumulates. We then evaluate Bayesian approaches compared with frequentist approaches through a series of simulation studies and a case study of ICD therapy in the prevention of sudden cardiac death. These analyses allow us to explore four decisional contexts in which CMS may consider the use of Bayesian approaches, namely where clinical trial results appear to demonstrate greater or lesser efficacy in particular subgroups (and applicants are wanting to determine whether the evidence supporting the intervention’s efficacy in these subgroups is sufficient from CMS’ viewpoint), where trial results focus on patient populations different from CMS beneficiaries, and where applicants are designing a new trial based on previous findings. In addition, as CMS considers the use of Bayesian and frequentist approaches in their decisional contexts, Bayesian techniques allow for ease of integration and consistency with a decision analytic framework.

Based on our work, we provide suggestions to CMS concerning the use of Bayesian statistical approaches in policymaking. Incorporation of these findings into CMS decisionmaking process may enable policymakers to harness the power of the available sources of clinical evidence, explore subgroup effects within a trial and across trials in a methodologically rigorous manner, assess the uncertainty in clinical trial findings – and ideally improve health outcomes for Medicare beneficiaries.