# ICD Case Study (Executive Summary)

## Introduction

In this section we provide an executive summary of our case study in terms of the analyses performed and our key findings. For the interested reader, in the Appendix we provide additional details (both in terms of our methods and assumptions but also tables and figures of our findings). More technical details will be published in a statistical manuscript. In this executive summary, references to the tables in the Appendix are for the sake of completeness.

Prior to the case study described in this section, we performed substantial simulation studies to demonstrate that while single trials may be adequately powered to detect main treatment effects, they often have low power to detect treatment-covariate interactions. Furthermore, these studies demonstrated that combining data from trials improves the power to detect such treatment-covariate interactions. Details about the simulation studies and our findings may be obtained from the authors and will be published in a statistical manuscript. To explore the findings from our simulation studies and to provide evidence concerning the advantages and disadvantages of Bayesian techniques in clinical trial design and analysis, we performed a case study of the use of ICD therapy in the prevention of SCD using data from eight clinical trials.

## Methods and Assumptions

For the purposes of this case study, we considered data from eight trials (AVID, CABG-PATCH, CASH, DEFINITE, MADIT-I, MADIT-II, MUSTT and SCD-HeFT). For any trial, the overall survival (in years from randomization) is the primary outcome. There are two treatment groups (ICD versus control) and four baseline prognostic variables, namely, age (in years), ejection fraction (given as a percent), NYHA class (Classes I through IV) and ischemic disease (yes/no). We assumed that the four prognostic variables also capture differences in the trial designs.

Besides the clinical trial data, we received ICD Registry data (limited to Medicare patients) from CMS, which includes 121,398 implants between 12/31/2004 and 6/30/2007. The registry data do not include non-implanted controls and do not have followup information regarding patients’ overall survival. Thus, for the purpose of illustration, we utilized registry data from the MUSTT study to address survival comparisons considering clinical trial and registry data.

We performed four sets of analyses. These analyses focused on the use of data from individual trials, combining data from all trials, exploring the use of registry data, and then evaluating the impact of access to aggregate versus patient level data.

In the analysis of the individual trials, we used models to compare overall survival by treatment groups. To most fully explore the impact of classical and Bayesian approaches we considered both an unadjusted analysis considering data from all patients in the trial as well as stratified analysis on subgroups. We also considered analysis that adjusted for the common set of baseline prognostic variables, both, with and without the interaction between each of the baseline prognostic variables and treatment. Note that statistical interaction means the effect of one independent variable(s) on the dependent variable depends on the value of another independent variable(s).

We then performed a set of analyses where we combined data from all of the trials. We considered models that included or not the interactions between baseline prognostic variables and treatment. To combine data from all trials we considered four model variations: 1) combining data from all trials, but without adjusting for (potential) trial effects; 2) combining data from all trials adjusting for trial effects assuming a fixed effect for trial; 3) combining data from all trials assuming random effects for trial and 4) combining data from all trials assuming trial-specific baseline hazard functions. Bayesian estimation was also performed in the models. We additionally considered a full hierarchical model utilizing random effects for baseline hazard functions, main, and interaction effects. We performed sensitivity analyses on the priors used in our Bayesian analyses.

In the analysis of registry data we used Bayesian techniques to simulate the survival experience of hypothetical patients in a hypothetical new trial under the ICD and control groups in given prognostic subgroups. Using these samples we obtained the posterior predictive survival distributions for the ICD and control groups which can then be compared to the empirical survival distribution of the related subgroups in the registry data.

Finally, one critical aspect of our analysis is the availability of patient-level data from ICD trials. In practice, however, data analysts may face a situation in which only aggregate data are available; for example, in the form of estimates of the treatment effect along with estimated standard errors. Such data become available sequentially as trial results get published. We, thus, performed additional analyses to investigate two additional points:

1. What are the implications of using aggregate data as opposed to using patient-level data in assessing overall ICD efficacy?
2. By considering the accumulated sequential evidence from trials, either using aggregate or patient-level data, would we be able to reach a conclusive decision of overall ICD efficacy sooner?

We explored these questions under alternative models and choices of prior to explore their impact on our findings. Finally, using patient-level data, we also considered the accumulated sequential evidence from trials to assess treatment-covariate interactions across prognostic subgroups.

As noted, additional details on our methods (and findings) are provided for the reader in the Appendix. Technical details of the statistical models explored are available from the authors and will be published in a statistical manuscript.

## Findings

### Analysis of Individual Trials

Summary statistics for each trial by treatment group are shown in Table 4 (Parts 1 and 2). The table shows that the trials considered in this case study differ in sample size with the smallest trial having 196 patients (MADIT-I) and the largest with 1676 (SCD-HeFT) patients randomized to ICD and control. Participants have different compositions across trials. For example, some trials such as CABG-PATCH, MADIT-I, MADIT-II and MUSTT had only ischemic patients while the DEFINITE trial only included non-ischemic patients.

Figures 11(a) and 11(b) show the Kaplan-Meier survival curves by trial and treatment group. In the analysis of individual trials, without adjusting for prognostic variables, there is evidence of treatment effect on overall survival in five trials (AVID, MADIT-I, MADIT-II, MUSTT and SCD-HeFT) (see Table 5). Among trials that showed treatment effect, the estimated hazard ratio (for death from all causes in the ICD group as compared to the control group) ranged from 0.35 to 0.75. Among trials that did not show treatment effect, the estimated hazard ratio ranged from 0.65 to 1.07.

Figure 11 (a) Kaplan-Meier survival curves by treatment group

Figure 11 (b) Kaplan-Meier survival curves by treatment group. (Note that in the SCD-HeFT trial the dotted red line corresponds to the “placebo” arm of the trial.)

Table 5 Comparison of overall survival by treatment group within each trial, unadjusted Cox-Proportional Hazards Model

Trial | Sample Size | | Number of Events | | Hazard Ratio | 95% CI | | P-value
Trial | Control | ICD | Control | ICD | Hazard Ratio | 95% CI | | P-value
AVID | 509 | 507 | 122 | 80 | 0.61 | 0.46 | 0.81 | < 0.001
CABG-PATCH | 454 | 446 | 95 | 101 | 1.07 | 0.81 | 1.42 | 0.635
CASH | 189 | 99 | 71 | 37 | 0.89 | 0.60 | 1.32 | 0.549
DEFINITE | 229 | 229 | 40 | 28 | 0.65 | 0.40 | 1.06 | 0.08
MADIT-I | 101 | 95 | 39 | 17 | 0.35 | 0.19 | 0.63 | < 0.001
MADIT-II | 490 | 742 | 105 | 107 | 0.65 | 0.50 | 0.85 | 0.002
MUSTT | 353 | 167 | 158 | 35 | 0.42 | 0.29 | 0.60 | < 0.001
SCD-HeFT | 847 | 829 | 284 | 182 | 0.75 | 0.62 | 0.91 | 0.004

Abbreviations for Table 5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; CI = confidence interval; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; ICD = implantable cardioverter defibrillator; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Comparisons of overall survival by treatment group within prognostic subgroups in general failed to show an association between treatment and overall survival (see Table 6). Most entries in the table with significant results were no longer significant when considering Bonferroni’s adjustment to account for multiple testing. The only exception was in subgroup 4 (age < 65, EF < 30 percent, NYHA II and ischemic disease) in the SCD-HeFT trial (Bonferroni’s adjusted p-value < 0.001). We note that these results are affected by the small sample sizes in each subgroup (Table 7 [Parts 1–5]).

Table 6 Comparison of overall survival by treatment group within each trial, stratified analysis^*^

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | AVID | CABG- PATCH | CASH | DEFINITE | MADIT-I | MADIT-II | MUSTT | SCD- HeFT
1 | < 65 | ≤ 30% | 1 | Non-Isch | 0.29 (0.03, 2.37) | - | - | 0.58 (0.10, 3.45) | - | - | - | -
2 | < 65 | ≤ 30% | 1 | Isch | 0.65 (0.23, 1.79) | 0.54 (0.22, 1.36) | - | - | - | 0.66 (0.27, 1.62) | 0.79 (0.19, 3.32) | -
3 | < 65 | ≤ 30% | 2 | Non-Isch | 0.69 (0.04, 11.1) | - | - | 0.85 (0.34, 2.15) | - | - | - | 0.67 (0.35, 1.32)
4 | < 65 | ≤ 30% | 2 | Isch | 0.62 (0.21, 1.82) | 1.27 (0.46, 3.51) | 0.14 (0.03, 0.64) | - | 0.47 (0.12, 1.78) | 0.49 (0.19, 1.25) | 0.14 (0.02, 1.06) | 0.33 (0.17, 0.62)
5 | < 65 | ≤ 30% | 3 | Non-Isch | - | - | - | 0.49 (0.12, 2.04) | - | - | - | 0.95 (0.43, 2.10)
6 | < 65 | ≤ 30% | 3 | Isch | 0.51 (0.14, 1.87) | 0.84 (0.23, 3.16) | 5.88 (0.61, 56.9) | - | 0.46 (0.09, 2.38) | 0.81 (0.33, 1.94) | 0.92 (0.30, 2.83) | 0.71 (0.40, 1.29)
7 | < 65 | ≤ 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
8 | < 65 | ≤ 30% | 4 | Isch | - | 0.52 (0.12, 2.33) | - | - | - | 1.92 (0.36, 10.1) | - | -
9 | < 65 | > 30% | 1 | Non-Isch | - | - | - | - | - | - | - | -
10 | < 65 | > 30% | 1 | Isch | 1.03 (0.28, 3.82) | 0.81 (0.18, 3.63) | 0.37 (0.04, 3.08) | - | - | - | 2.00 (0.12, 32.9) | -
11 | < 65 | > 30% | 2 | Non-Isch | 0.80 (0.07, 8.90) | - | 0.50 (0.03, 8.46) | - | - | - | - | 1.04 (0.38, 2.87)
12 | < 65 | > 30% | 2 | Isch | 1.24 (0.11, 13.8) | - | 0.85 (0.34, 2.15) | - | 0.14 (0.01, 1.59) | - | - | 0.86 (0.40, 1.86)
13 | < 65 | > 30% | 3 | Non-Isch | - | - | - | - | - | - | - | 0.21 (0.02, 1.86)
14 | < 65 | > 30% | 3 | Isch | - | 0.91 (0.18, 4.50) | 1.42 (0.26, 7.80) | - | - | - | 0.47 (0.04, 5.35) | 1.60 (0.68, 3.81)
15 | < 65 | > 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
16 | < 65 | > 30% | 4 | Isch | - | - | - | - | - | - | - | -
17 | [65,75) | ≤ 30% | 1 | Non-Isch | - | - | - | 0.36 (0.04, 3.44) | - | - | - | -
18 | [65,75) | ≤ 30% | 1 | Isch | 0.65 (0.27, 1.57) | 0.98 (0.46, 2.07) | - | - | 0.45 (0.04, 5.02) | 0.49 (0.22, 1.06) | 0.61 (0.13, 2.93) | -
19 | [65,75) | ≤ 30% | 2 | Non-Isch | - | - | - | 1.24 (0.31, 4.98) | - | - | - | 0.76 (0.31, 1.87)
20 | [65,75) | ≤ 30% | 2 | Isch | 0.39 (0.12, 1.22) | 1.53 (0.58, 4.05) | 0.31 (0.03, 3.48) | - | 0.38 (0.11, 1.32) | 0.89 (0.42, 1.90) | 0.38 (0.10, 1.44) | 0.71 (0.36, 1.40)
21 | [65,75) | ≤ 30% | 3 | Non-Isch | - | - | - | 0.60 (0.15, 2.33) | - | - | - | 0.88 (0.37, 2.11)
22 | [65,75) | ≤ 30% | 3 | Isch | 0.33 (0.04, 2.76) | 1.28 (0.53, 3.10) | 1.09 (0.09, 13.3) | - | 0.23 (0.04, 1.32) | 0.29 (0.13, 0.68) | 0.14 (0.03, 0.64) | 1.42 (0.70, 2.86)
23 | [65,75) | ≤ 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
24 | [65,75) | ≤ 30% | 4 | Isch | - | - | - | - | - | 1.27 (0.33, 4.89) | - | -
25 | [65,75) | > 30% | 1 | Non-Isch | - | - | - | - | - | - | - | -
26 | [65,75) | > 30% | 1 | Isch | 0.83 (0.34, 2.00) | 1.01 (0.30, 3.34) | - | - | - | - | 1.60 (0.10, 25.7) | -
27 | [65,75) | > 30% | 2 | Non-Isch | - | - | - | - | - | - | - | 0.80 (0.19, 3.35)
28 | [65,75) | > 30% | 2 | Isch | 0.60 (0.13, 2.70) | 0.48 (0.04, 5.35) | 2.20 (0.55, 8.76) | - | - | - | - | 0.08 (0.01, 0.61)
29 | [65,75) | > 30% | 3 | Non-Isch | - | - | - | - | - | - | - | -
30 | [65,75) | > 30% | 3 | Isch | - | 0.27 (0.03, 2.64) | 2.14 (0.51, 9.08) | - | - | - | - | 2.46 (0.83, 7.23)
31 | [65,75) | > 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
32 | [65,75) | > 30% | 4 | Isch | - | 0.52 (0.09, 3.20) | - | - | - | - | - | -
33 | ≥ 75 | ≤ 30% | 1 | Non-Isch | - | | - | (0.18 0.03, 1.33) | - | | - | -
34 | ≥ 75 | ≤ 30% | 1 | Isch | 0.92 (0.29, 2.92) | 2.27 (0.47, 11.0) | - | - | - | 0.74 (0.27, 1.99) | 6.36 (0.38, 106) | -
35 | ≥ 75 | ≤ 30% | 2 | Non-Isch | 0.47 (0.03, 7.86) | - | - | 1.27 (0.12, 14.0) | - | - | - | 0.24 (0.03, 1.97)
36 | ≥ 75 | ≤ 30% | 2 | Isch | 1.03 (0.36, 2.98) | 2.31 (0.21, 25.5) | - | - | - | 0.26 (0.07, 0.99) | 0.85 (0.08, 9.44) | 0.15 (0.02, 1.16)
37 | ≥ 75 | ≤ 30% | 3 | Non-Isch | - | - | - | 0.11 (0.01, 1.10) | - | - | - | 0.18 (0.01, 2.93)
38 | ≥ 75 | ≤ 30% | 3 | Isch | 0.62 (0.06, 5.96) | 1.14 (0.40, 3.27) | - | - | - | 0.60 (0.27, 1.34) | - | 0.88 (0.33, 2.36)
39 | ≥ 75 | ≤ 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
40 | ≥ 75 | ≤ 30% | 4 | Isch | - | - | - | - | - | - | - | -
41 | ≥ 75 | > 30% | 1 | Non-Isch | - | - | - | - | - | - | - | -
42 | ≥ 75 | > 30% | 1 | Isch | 1.25 (0.35, 4.43) | 0.38 (0.04, 3.63) | - | - | - | - | - | -
43 | ≥ 75 | > 30% | 2 | Non-Isch | - | - | - | - | - | - | - | 0.39 (0.04, 3.52)
44 | ≥ 75 | > 30% | 2 | Isch | 1.08 (0.10, 11.9) | - | 0.84 (0.07, 9.61) | - | - | - | 3.47 (0.31, 38.4) | 0.75 (0.15, 3.70)
45 | ≥ 75 | > 30% | 3 | Non-Isch | - | - | - | - | - | - | - | -
46 | ≥ 75 | > 30% | 3 | Isch | - | - | - | - | - | - | - | -
47 | ≥ 75 | > 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
48 | ≥ 75 | > 30% | 4 | Isch | - | - | - | - | - | - | - | -

* For each cell, entries give estimated hazard ratio and 95% confidence interval (unadjusted for multiple testing) comparing survival by treatment in the subgroups of interest. Missing entries indicate unavailable data for the particular subgroup. Entries highlighted in red indicate significant results at the unadjusted significance level of 5%.

Abbreviations for Table 6: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Table 7 – Part 1 Subgroup composition by treatment group and trial – (all trials)

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | All Trials
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | Control | | ICD
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | #Subjects | #Events | #Subjects | #Events
1 | < 65 | ≤30% | 1 | Non-Isch | 45 | 9 | 42 | 3
2 | < 65 | ≤30% | 1 | Isch | 247 | 39 | 295 | 28
3 | < 65 | ≤30% | 2 | Non-Isch | 240 | 33 | 227 | 24
4 | < 65 | ≤30% | 2 | Isch | 306 | 96 | 302 | 40
5 | < 65 | ≤30% | 3 | Non-Isch | 92 | 21 | 82 | 17
6 | < 65 | ≤30% | 3 | Isch | 171 | 68 | 188 | 51
7 | < 65 | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0
8 | < 65 | ≤30% | 4 | Isch | 16 | 6 | 27 | 8
9 | < 65 | > 30% | 1 | Non-Isch | 15 | 3 | 9 | 1
10 | < 65 | > 30% | 1 | Isch | 173 | 15 | 156 | 10
11 | < 65 | > 30% | 2 | Non-Isch | 94 | 10 | 98 | 10
12 | < 65 | > 30% | 2 | Isch | 157 | 35 | 135 | 22
13 | < 65 | > 30% | 3 | Non-Isch | 23 | 6 | 30 | 1
14 | < 65 | > 30% | 3 | Isch | 58 | 19 | 50 | 19
15 | < 65 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0
16 | < 65 | > 30% | 4 | Isch | 2 | 0 | 6 | 1
17 | [65,75) | ≤30% | 1 | Non-Isch | 18 | 5 | 20 | 1
18 | [65,75) | ≤30% | 1 | Isch | 222 | 53 | 211 | 34
19 | [65,75) | ≤30% | 2 | Non-Isch | 74 | 14 | 78 | 14
20 | [65,75) | ≤30% | 2 | Isch | 198 | 64 | 249 | 61
21 | [65,75) | ≤30% | 3 | Non-Isch | 37 | 17 | 32 | 15
22 | [65,75) | ≤30% | 3 | Isch | 128 | 65 | 133 | 49
23 | [65,75) | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0
24 | [65,75) | ≤30% | 4 | Isch | 20 | 4 | 24 | 8
25 | [65,75) | > 30% | 1 | Non-Isch | 4 | 3 | 3 | 0
26 | [65,75) | > 30% | 1 | Isch | 98 | 17 | 101 | 16
27 | [65,75) | > 30% | 2 | Non-Isch | 21 | 5 | 19 | 4
28 | [65,75) | > 30% | 2 | Isch | 110 | 35 | 74 | 8
29 | [65,75) | > 30% | 3 | Non-Isch | 13 | 1 | 7 | 2
30 | [65,75) | > 30% | 3 | Isch | 37 | 17 | 33 | 16
31 | [65,75) | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0
32 | [65,75) | > 30% | 4 | Isch | 5 | 3 | 4 | 2
33 | ≥75 | ≤30% | 1 | Non-Isch | 3 | 2 | 12 | 3
34 | ≥75 | ≤30% | 1 | Isch | 80 | 21 | 92 | 22
35 | ≥75 | ≤30% | 2 | Non-Isch | 20 | 8 | 22 | 4
36 | ≥75 | ≤30% | 2 | Isch | 77 | 28 | 76 | 16
37 | ≥75 | ≤30% | 3 | Non-Isch | 5 | 4 | 16 | 3
38 | ≥75 | ≤30% | 3 | Isch | 67 | 35 | 78 | 33
39 | ≥75 | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0
40 | ≥75 | ≤30% | 4 | Isch | 6 | 1 | 7 | 3
41 | ≥75 | > 30% | 1 | Non-Isch | 2 | 0 | 1 | 1
42 | ≥75 | > 30% | 1 | Isch | 42 | 8 | 43 | 7
43 | ≥75 | > 30% | 2 | Non-Isch | 7 | 4 | 4 | 1
44 | ≥75 | > 30% | 2 | Isch | 34 | 10 | 36 | 8
45 | ≥75 | > 30% | 3 | Non-Isch | 3 | 1 | 6 | 0
46 | ≥75 | > 30% | 3 | Isch | 10 | 5 | 11 | 5
47 | ≥75 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0
48 | ≥75 | > 30% | 4 | Isch | 0 | 0 | 0 | 0

Abbreviations for Table 7 – Parts 1–5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ICD = implantable cardioverter defibrillator; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Table 7 – Part 2 Subgroup composition by treatment group and trial – (AVID and CABG-PATCH)

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | AVID | | | | CABG-PATCH
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | Control | | ICD | | Control | | ICD
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events
1 | < 65 | ≤30% | 1 | Non-Isch | 16 | 6 | 8 | 1 | 0 | 0 | 0 | 0
2 | < 65 | ≤30% | 1 | Isch | 38 | 7 | 62 | 8 | 84 | 13 | 83 | 7
3 | < 65 | ≤30% | 2 | Non-Isch | 9 | 1 | 14 | 1 | 0 | 0 | 0 | 0
4 | < 65 | ≤30% | 2 | Isch | 31 | 11 | 28 | 5 | 35 | 7 | 34 | 8
5 | < 65 | ≤30% | 3 | Non-Isch | 9 | 0 | 4 | 2 | 0 | 0 | 0 | 0
6 | < 65 | ≤30% | 3 | Isch | 15 | 10 | 8 | 3 | 28 | 5 | 24 | 6
7 | < 65 | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8 | < 65 | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 8 | 4 | 12 | 3
9 | < 65 | > 30% | 1 | Non-Isch | 7 | 0 | 5 | 0 | 0 | 0 | 0 | 0
10 | < 65 | > 30% | 1 | Isch | 72 | 4 | 78 | 5 | 47 | 4 | 43 | 3
11 | < 65 | > 30% | 2 | Non-Isch | 5 | 2 | 5 | 1 | 0 | 0 | 0 | 0
12 | < 65 | > 30% | 2 | Isch | 11 | 1 | 13 | 2 | 12 | 1 | 8 | 0
13 | < 65 | > 30% | 3 | Non-Isch | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
14 | < 65 | > 30% | 3 | Isch | 2 | 1 | 2 | 0 | 10 | 3 | 11 | 3
15 | < 65 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16 | < 65 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 2 | 0 | 6 | 1
17 | [65,75) | ≤30% | 1 | Non-Isch | 10 | 2 | 10 | 0 | 0 | 0 | 0 | 0
18 | [65,75) | ≤30% | 1 | Isch | 56 | 13 | 53 | 8 | 74 | 16 | 57 | 12
19 | [65,75) | ≤30% | 2 | Non-Isch | 5 | 0 | 7 | 1 | 0 | 0 | 0 | 0
20 | [65,75) | ≤30% | 2 | Isch | 31 | 11 | 24 | 4 | 21 | 6 | 30 | 13
21 | [65,75) | ≤30% | 3 | Non-Isch | 3 | 0 | 1 | 1 | 0 | 0 | 0 | 0
22 | [65,75) | ≤30% | 3 | Isch | 16 | 7 | 5 | 1 | 23 | 9 | 21 | 11
23 | [65,75) | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
24 | [65,75) | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 10 | 0 | 12 | 3
25 | [65,75) | > 30% | 1 | Non-Isch | 3 | 2 | 3 | 0 | 0 | 0 | 0 | 0
26 | [65,75) | > 30% | 1 | Isch | 52 | 11 | 52 | 9 | 28 | 5 | 31 | 6
27 | [65,75) | > 30% | 2 | Non-Isch | 0 | 0 | 4 | 0 | 0 | 0 | 0 | 0
28 | [65,75) | > 30% | 2 | Isch | 19 | 4 | 21 | 3 | 8 | 2 | 7 | 1
29 | [65,75) | > 30% | 3 | Non-Isch | 2 | 0 | 1 | 1 | 0 | 0 | 0 | 0
30 | [65,75) | > 30% | 3 | Isch | 2 | 1 | 3 | 0 | 5 | 3 | 4 | 1
31 | [65,75) | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
32 | [65,75) | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 5 | 3 | 4 | 2
33 | ≥75 | ≤30% | 1 | Non-Isch | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0
34 | ≥75 | ≤30% | 1 | Isch | 27 | 7 | 23 | 5 | 12 | 2 | 21 | 7
35 | ≥75 | ≤30% | 2 | Non-Isch | 2 | 1 | 4 | 1 | 0 | 0 | 0 | 0
36 | ≥75 | ≤30% | 2 | Isch | 17 | 9 | 14 | 6 | 8 | 1 | 7 | 4
37 | ≥75 | ≤30% | 3 | Non-Isch | 0 | 0 | 3 | 1 | 0 | 0 | 0 | 0
38 | ≥75 | ≤30% | 3 | Isch | 8 | 3 | 4 | 1 | 15 | 7 | 12 | 7
39 | ≥75 | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
40 | ≥75 | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 4 | 1 | 1 | 0
41 | ≥75 | > 30% | 1 | Non-Isch | 2 | 0 | 1 | 1 | 0 | 0 | 0 | 0
42 | ≥75 | > 30% | 1 | Isch | 25 | 4 | 30 | 6 | 13 | 3 | 12 | 1
43 | ≥75 | > 30% | 2 | Non-Isch | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0
44 | ≥75 | > 30% | 2 | Isch | 5 | 1 | 10 | 2 | 1 | 0 | 1 | 1
45 | ≥75 | > 30% | 3 | Non-Isch | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0
46 | ≥75 | > 30% | 3 | Isch | 2 | 1 | 2 | 0 | 0 | 0 | 1 | 1
47 | ≥75 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
48 | ≥75 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

Abbreviations for Table 7 – Parts 1–5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ICD = implantable cardioverter defibrillator; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Table 7 – Part 3 Subgroup composition by treatment group and trial – (CASH and DEFINITE)

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | CASH | | | | DEFINITE
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | Control | | ICD | | Control | | ICD
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events
1 | < 65 | ≤30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 29 | 3 | 34 | 2
2 | < 65 | ≤30% | 1 | Isch | 3 | 1 | 1 | 1 | 0 | 0 | 0 | 0
3 | < 65 | ≤30% | 2 | Non-Isch | 1 | 0 | 2 | 1 | 89 | 10 | 78 | 8
4 | < 65 | ≤30% | 2 | Isch | 16 | 11 | 9 | 2 | 0 | 0 | 0 | 0
5 | < 65 | ≤30% | 3 | Non-Isch | 2 | 2 | 1 | 0 | 24 | 5 | 29 | 3
6 | < 65 | ≤30% | 3 | Isch | 5 | 2 | 5 | 4 | 0 | 0 | 0 | 0
7 | < 65 | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8 | < 65 | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
9 | < 65 | > 30% | 1 | Non-Isch | 7 | 3 | 1 | 0 | 1 | 0 | 3 | 1
10 | < 65 | > 30% | 1 | Isch | 39 | 6 | 17 | 1 | 0 | 0 | 0 | 0
11 | < 65 | > 30% | 2 | Non-Isch | 5 | 1 | 4 | 1 | 8 | 0 | 2 | 0
12 | < 65 | > 30% | 2 | Isch | 45 | 13 | 26 | 7 | 0 | 0 | 0 | 0
13 | < 65 | > 30% | 3 | Non-Isch | 1 | 1 | 0 | 0 | 2 | 1 | 2 | 0
14 | < 65 | > 30% | 3 | Isch | 4 | 2 | 5 | 4 | 0 | 0 | 0 | 0
15 | < 65 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16 | < 65 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
17 | [65,75) | ≤30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 8 | 3 | 10 | 1
18 | [65,75) | ≤30% | 1 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
19 | [65,75) | ≤30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 34 | 4 | 30 | 4
20 | [65,75) | ≤30% | 2 | Isch | 3 | 2 | 4 | 3 | 0 | 0 | 0 | 0
21 | [65,75) | ≤30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 18 | 7 | 9 | 3
22 | [65,75) | ≤30% | 3 | Isch | 4 | 3 | 1 | 1 | 0 | 0 | 0 | 0
23 | [65,75) | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
24 | [65,75) | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25 | [65,75) | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0
26 | [65,75) | > 30% | 1 | Isch | 1 | 0 | 5 | 0 | 0 | 0 | 0 | 0
27 | [65,75) | > 30% | 2 | Non-Isch | 0 | 0 | 1 | 1 | 1 | 0 | 2 | 0
28 | [65,75) | > 30% | 2 | Isch | 19 | 8 | 5 | 3 | 0 | 0 | 0 | 0
29 | [65,75) | > 30% | 3 | Non-Isch | 1 | 1 | 0 | 0 | 1 | 0 | 0 | 0
30 | [65,75) | > 30% | 3 | Isch | 5 | 5 | 6 | 5 | 0 | 0 | 0 | 0
31 | [65,75) | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
32 | [65,75) | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
33 | ≥75 | ≤30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 2 | 2 | 11 | 3
34 | ≥75 | ≤30% | 1 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
35 | ≥75 | ≤30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 7 | 1 | 11 | 2
36 | ≥75 | ≤30% | 2 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
37 | ≥75 | ≤30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 4 | 3 | 7 | 1
38 | ≥75 | ≤30% | 3 | Isch | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0
39 | ≥75 | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
40 | ≥75 | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
41 | ≥75 | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
42 | ≥75 | > 30% | 1 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
43 | ≥75 | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0
44 | ≥75 | > 30% | 2 | Isch | 5 | 2 | 2 | 1 | 0 | 0 | 0 | 0
45 | ≥75 | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
46 | ≥75 | > 30% | 3 | Isch | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0
47 | ≥75 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
48 | ≥75 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

Abbreviations for Table 7 – Parts 1–5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ICD = implantable cardioverter defibrillator; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Table 7 – Part 4 Subgroup composition by treatment group and trial – (MADIT-I and MADIT-II)

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | MADIT-I | | | | MADIT-II
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | Control | | ICD | | Control | | ICD
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events
1 | < 65 | ≤30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
2 | < 65 | ≤30% | 1 | Isch | 14 | 3 | 12 | 0 | 91 | 10 | 124 | 9
3 | < 65 | ≤30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
4 | < 65 | ≤30% | 2 | Isch | 21 | 8 | 15 | 3 | 81 | 10 | 115 | 8
5 | < 65 | ≤30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
6 | < 65 | ≤30% | 3 | Isch | 9 | 5 | 7 | 2 | 44 | 8 | 87 | 13
7 | < 65 | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8 | < 65 | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 8 | 2 | 15 | 5
9 | < 65 | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
10 | < 65 | > 30% | 1 | Isch | 2 | 0 | 11 | 0 | 1 | 0 | 0 | 0
11 | < 65 | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
12 | < 65 | > 30% | 2 | Isch | 3 | 2 | 7 | 1 | 0 | 0 | 0 | 0
13 | < 65 | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
14 | < 65 | > 30% | 3 | Isch | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0
15 | < 65 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16 | < 65 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
17 | [65,75) | ≤30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
18 | [65,75) | ≤30% | 1 | Isch | 7 | 2 | 7 | 1 | 67 | 15 | 86 | 11
19 | [65,75) | ≤30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20 | [65,75) | ≤30% | 2 | Isch | 16 | 7 | 17 | 6 | 60 | 11 | 107 | 17
21 | [65,75) | ≤30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22 | [65,75) | ≤30% | 3 | Isch | 6 | 4 | 6 | 3 | 46 | 19 | 62 | 8
23 | [65,75) | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
24 | [65,75) | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 10 | 4 | 12 | 5
25 | [65,75) | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26 | [65,75) | > 30% | 1 | Isch | 5 | 0 | 5 | 0 | 0 | 0 | 0 | 0
27 | [65,75) | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28 | [65,75) | > 30% | 2 | Isch | 5 | 1 | 0 | 0 | 0 | 0 | 0 | 0
29 | [65,75) | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
30 | [65,75) | > 30% | 3 | Isch | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 0
31 | [65,75) | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
32 | [65,75) | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
33 | ≥75 | ≤30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
34 | ≥75 | ≤30% | 1 | Isch | 4 | 3 | 0 | 0 | 28 | 7 | 46 | 9
35 | ≥75 | ≤30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
36 | ≥75 | ≤30% | 2 | Isch | 5 | 1 | 2 | 0 | 23 | 7 | 37 | 3
37 | ≥75 | ≤30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
38 | ≥75 | ≤30% | 3 | Isch | 2 | 2 | 0 | 0 | 20 | 10 | 38 | 16
39 | ≥75 | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
40 | ≥75 | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 2 | 0 | 6 | 3
41 | ≥75 | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
42 | ≥75 | > 30% | 1 | Isch | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0
43 | ≥75 | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
44 | ≥75 | > 30% | 2 | Isch | 0 | 0 | 3 | 0 | 1 | 1 | 0 | 0
45 | ≥75 | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
46 | ≥75 | > 30% | 3 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
47 | ≥75 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
48 | ≥75 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

Abbreviations for Table 7 – Parts 1–5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ICD = implantable cardioverter defibrillator; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Table 7 – Part 5 Subgroup composition by treatment group and trial – (MUSTT and SCD-HeFT)

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | MUSTT | | | | SCD-HeFT
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | Control | | ICD | | Control | | ICD
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events
1 | < 65 | ≤30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
2 | < 65 | ≤30% | 1 | Isch | 17 | 5 | 13 | 3 | 0 | 0 | 0 | 0
3 | < 65 | ≤30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 141 | 22 | 133 | 14
4 | < 65 | ≤30% | 2 | Isch | 24 | 13 | 10 | 1 | 98 | 36 | 91 | 13
5 | < 65 | ≤30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 57 | 14 | 48 | 12
6 | < 65 | ≤30% | 3 | Isch | 15 | 9 | 10 | 5 | 55 | 29 | 47 | 18
7 | < 65 | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8 | < 65 | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
9 | < 65 | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
10 | < 65 | > 30% | 1 | Isch | 12 | 1 | 7 | 1 | 0 | 0 | 0 | 0
11 | < 65 | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 76 | 7 | 87 | 8
12 | < 65 | > 30% | 2 | Isch | 8 | 4 | 7 | 0 | 78 | 14 | 74 | 12
13 | < 65 | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 20 | 4 | 27 | 1
14 | < 65 | > 30% | 3 | Isch | 4 | 2 | 3 | 1 | 38 | 11 | 28 | 10
15 | < 65 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16 | < 65 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
17 | [65,75) | ≤30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
18 | [65,75) | ≤30% | 1 | Isch | 18 | 7 | 8 | 2 | 0 | 0 | 0 | 0
19 | [65,75) | ≤30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 35 | 10 | 41 | 9
20 | [65,75) | ≤30% | 2 | Isch | 18 | 8 | 14 | 3 | 49 | 19 | 53 | 15
21 | [65,75) | ≤30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 16 | 10 | 22 | 11
22 | [65,75) | ≤30% | 3 | Isch | 13 | 11 | 8 | 2 | 20 | 12 | 30 | 23
23 | [65,75) | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
24 | [65,75) | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25 | [65,75) | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26 | [65,75) | > 30% | 1 | Isch | 12 | 1 | 8 | 1 | 0 | 0 | 0 | 0
27 | [65,75) | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 20 | 5 | 12 | 3
28 | [65,75) | > 30% | 2 | Isch | 11 | 3 | 7 | 0 | 48 | 17 | 34 | 1
29 | [65,75) | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 9 | 0 | 6 | 1
30 | [65,75) | > 30% | 3 | Isch | 5 | 2 | 2 | 0 | 19 | 5 | 17 | 10
31 | [65,75) | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
32 | [65,75) | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
33 | ≥75 | ≤30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
34 | ≥75 | ≤30% | 1 | Isch | 9 | 2 | 2 | 1 | 0 | 0 | 0 | 0
35 | ≥75 | ≤30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 11 | 6 | 7 | 1
36 | ≥75 | ≤30% | 2 | Isch | 6 | 2 | 4 | 1 | 18 | 8 | 12 | 2
37 | ≥75 | ≤30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 1 | 1 | 6 | 1
38 | ≥75 | ≤30% | 3 | Isch | 9 | 5 | 5 | 0 | 12 | 7 | 19 | 9
39 | ≥75 | ≤30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
40 | ≥75 | ≤30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
41 | ≥75 | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
42 | ≥75 | > 30% | 1 | Isch | 3 | 1 | 0 | 0 | 0 | 0 | 0 | 0
43 | ≥75 | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 6 | 4 | 3 | 1
44 | ≥75 | > 30% | 2 | Isch | 8 | 3 | 1 | 1 | 14 | 3 | 19 | 3
45 | ≥75 | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 2 | 0 | 6 | 0
46 | ≥75 | > 30% | 3 | Isch | 3 | 3 | 1 | 0 | 4 | 0 | 7 | 4
47 | ≥75 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
48 | ≥75 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

Abbreviations for Table 7 – Parts 1–5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ICD = implantable cardioverter defibrillator; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

When we adjusted for prognostic variables, the model demonstrates evidence of treatment effect on overall survival in the trials previously identified as well as in the DEFINITE trial (Appendix Tables A5–A12). In general, there was no evidence of significant interactions when we explored the interaction between treatment and each of the prognostic variables. The exception was in CASH which showed significant treatment interaction with EF and NYHA class, MADIT-I with a significant interaction between treatment and EF and SCD-HeFT with a significant interaction between treatment and age and NYHA class.

Key points: The analysis of the individual trials shows that, out of eight trials, five showed evidence of treatment effect, but there is also a lot of variation in the estimates of ICD effect across trials. Within any trial, the results are fairly robust to different model formulations. Generally, there is no evidence of significant treatment-covariate interactions in the prognostic subgroups.

### Analysis of Data Combining All Trials

Under all model formulations considered here, there is evidence of treatment effect on overall survival (Appendix Tables A13–A17). Estimates from Bayesian models (Appendix Tables A18–A21), are generally similar to those obtained under the frequentist models. Note that the estimates have lower uncertainty as compared to those from the individual trials.

Appendix Table A22 shows estimates under the full Bayesian hierarchical model that accounts for trial variation in the baseline-hazard, main effects and interaction effects (note that hierarchical models are not limited to the Bayesian paradigm but are particularly natural within that way of thinking). To summarize the results we present the population estimates, as well as, the trial-specific estimates. We find differential effect of ICD across trials. In particular, we find no treatment effect in the CABG-PATCH and CASH (95 percent posterior credible intervals include the null value) trials. There is no evidence of interactions between treatment and any of the prognostic variables.

For ease of interpretation, in Table 8 we provide the median hazard ratios and the 95 percent credible intervals for the effect of treatment within the main subgroups defined by the prognostic variables for the individual trials and then for the entire population of trials. We also provide the posterior probability that the hazard ratio for the total mortality reduction from the ICD treatment would be 0.80 or less, as this was considered a clinically important reduction in mortality by members of our technical expert panel. For sensitivity analysis, we also present probabilities when using different clinical cutoffs, that is, of 0.70 and 0.90. So, for example, although the 95 percent credible interval for the overall hazard ratio for the reduction in mortality from ICD implant includes the value of no treatment efficacy (that is, a hazard ratio equal to 1), with 83 percent posterior probability the hazard ratio is 0.80 or less indicating a clinically significant reduction. However, if one looks at the findings for treatment and NHYA class 4 patients we observe that not only there is no evidence of a significant interaction, but that there is only a 49 percent probability that the hazard ratio is 0.80 or less. In Table 9, we provide the same information (median hazard ratios, 95 percent credible intervals, and posterior probability that the hazard ratio is less or equal to 0.70, 0.80 and 0.90) for each of the 48 subgroups. Again note that there is no evidence of treatment benefit in the individual subgroups. The probability that the hazard ratio is 0.80 or less, however, is at least 75 percent in 11 of the subgroups indicated in red in the table.

Table 8 Hazard ratios for the effect of treatment given main prognostic variables

Variable | Trial | Hazard Ratio | | | Probability HR ≤ 0.70 | Probability HR ≤ 0.80 | Probability HR ≤ 0.90
Variable | Trial | Lower | Median | Upper | Probability HR ≤ 0.70 | Probability HR ≤ 0.80 | Probability HR ≤ 0.90
ICD Effect | AVID | 0.50 | 0.64 | 0.85 | 0.71 | 0.93 | 0.98
ICD Effect | CABG-PATCH | 0.80 | 1.04 | 1.37 | 0.00 | 0.03 | 0.17
ICD Effect | CASH | 0.55 | 0.81 | 1.16 | 0.22 | 0.47 | 0.69
ICD Effect | DEFINITE | 0.36 | 0.58 | 0.90 | 0.78 | 0.92 | 0.97
ICD Effect | MADIT-I | 0.26 | 0.46 | 0.74 | 0.96 | 0.99 | 1.00
ICD Effect | MADIT-II | 0.47 | 0.62 | 0.82 | 0.78 | 0.96 | 0.99
ICD Effect | MUSTT | 0.27 | 0.41 | 0.62 | 0.99 | 1.00 | 1.00
ICD Effect | SCD-HeFT | 0.62 | 0.73 | 0.87 | 0.31 | 0.83 | 0.99
ICD Effect | Overall | 0.41 | 0.64 | 1.02 | 0.64 | 0.83 | 0.93
ICD and Age [65,75) Effect | AVID | 0.24 | 0.58 | 1.29 | 0.69 | 0.81 | 0.88
ICD and Age [65,75) Effect | CABG-PATCH | 0.31 | 0.76 | 1.83 | 0.44 | 0.55 | 0.65
ICD and Age [65,75) Effect | CASH | 0.24 | 0.67 | 1.76 | 0.56 | 0.63 | 0.70
ICD and Age [65,75) Effect | DEFINITE | 0.27 | 0.75 | 1.70 | 0.43 | 0.56 | 0.67
ICD and Age [65,75) Effect | MADIT-I | 0.16 | 0.50 | 1.73 | 0.73 | 0.79 | 0.84
ICD and Age [65,75) Effect | MADIT-II | 0.21 | 0.63 | 1.41 | 0.56 | 0.65 | 0.72
ICD and Age [65,75) Effect | MUSTT | 0.14 | 0.51 | 1.66 | 0.71 | 0.77 | 0.82
ICD and Age [65,75) Effect | SCD-HeFT | 0.51 | 0.96 | 1.79 | 0.19 | 0.31 | 0.43
ICD and Age [65,75) Effect | Overall | 0.30 | 0.67 | 1.48 | 0.55 | 0.68 | 0.79
ICD and Age 75+ Effect | AVID | 0.41 | 0.84 | 2.04 | 0.31 | 0.43 | 0.57
ICD and Age 75+ Effect | CABG-PATCH | 0.38 | 0.96 | 2.51 | 0.26 | 0.35 | 0.44
ICD and Age 75+ Effect | CASH | 0.06 | 0.34 | 1.62 | 0.82 | 0.86 | 0.90
ICD and Age 75+ Effect | DEFINITE | 0.15 | 0.48 | 1.37 | 0.76 | 0.81 | 0.86
ICD and Age 75+ Effect | MADIT-I | 0.05 | 0.32 | 1.72 | 0.82 | 0.86 | 0.89
ICD and Age 75+ Effect | MADIT-II | 0.20 | 0.71 | 1.75 | 0.49 | 0.60 | 0.69
ICD and Age 75+ Effect | MUSTT | 0.13 | 0.56 | 2.16 | 0.62 | 0.68 | 0.73
ICD and Age 75+ Effect | SCD-HeFT | 0.26 | 0.60 | 1.34 | 0.63 | 0.76 | 0.83
ICD and Age 75+ Effect | Overall | 0.24 | 0.57 | 1.31 | 0.68 | 0.78 | 0.86
ICD and EF ≥ 30% Effect | AVID | 0.36 | 0.85 | 2.68 | 0.34 | 0.45 | 0.55
ICD and EF ≥ 30% Effect | CABG-PATCH | 0.19 | 0.49 | 1.20 | 0.81 | 0.90 | 0.93
ICD and EF ≥ 30% Effect | CASH | 0.23 | 0.60 | 1.41 | 0.66 | 0.77 | 0.84
ICD and EF ≥ 30% Effect | DEFINITE | 0.12 | 0.62 | 2.55 | 0.57 | 0.64 | 0.70
ICD and EF ≥ 30% Effect | MADIT-I | 0.07 | 0.36 | 1.74 | 0.79 | 0.82 | 0.85
ICD and EF ≥ 30% Effect | MADIT-II | 0.08 | 0.70 | 4.45 | 0.50 | 0.56 | 0.60
ICD and EF ≥ 30% Effect | MUSTT | 0.13 | 0.51 | 2.05 | 0.66 | 0.72 | 0.77
ICD and EF ≥ 30% Effect | SCD-HeFT | 0.48 | 0.99 | 2.04 | 0.22 | 0.32 | 0.41
ICD and EF ≥ 30% Effect | Overall | 0.27 | 0.62 | 1.57 | 0.62 | 0.73 | 0.80
ICD and NYHA II Effect | AVID | 0.26 | 0.57 | 1.18 | 0.69 | 0.81 | 0.89
ICD and NYHA II Effect | CABG-PATCH | 0.36 | 0.84 | 2.32 | 0.34 | 0.46 | 0.56
ICD and NYHA II Effect | CASH | 0.15 | 0.39 | 0.90 | 0.90 | 0.95 | 0.97
ICD and NYHA II Effect | DEFINITE | 0.38 | 0.78 | 1.51 | 0.37 | 0.53 | 0.64
ICD and NYHA II Effect | MADIT-I | 0.18 | 0.60 | 2.02 | 0.61 | 0.70 | 0.76
ICD and NYHA II Effect | MADIT-II | 0.21 | 0.62 | 1.67 | 0.58 | 0.68 | 0.74
ICD and NYHA II Effect | MUSTT | 0.09 | 0.36 | 1.05 | 0.86 | 0.91 | 0.94
ICD and NYHA II Effect | SCD-HeFT | 0.30 | 0.45 | 0.67 | 0.98 | 1.00 | 1.00
ICD and NYHA II Effect | Overall | 0.24 | 0.55 | 1.24 | 0.72 | 0.82 | 0.88
ICD and NYHA III Effect | AVID | 0.24 | 0.57 | 1.40 | 0.70 | 0.78 | 0.85
ICD and NYHA III Effect | CABG-PATCH | 0.27 | 0.65 | 1.64 | 0.56 | 0.67 | 0.74
ICD and NYHA III Effect | CASH | 0.29 | 0.80 | 1.99 | 0.40 | 0.50 | 0.60
ICD and NYHA III Effect | DEFINITE | 0.14 | 0.37 | 0.82 | 0.92 | 0.97 | 0.98
ICD and NYHA III Effect | MADIT-I | 0.12 | 0.48 | 1.71 | 0.72 | 0.78 | 0.83
ICD and NYHA III Effect | MADIT-II | 0.18 | 0.60 | 1.36 | 0.60 | 0.69 | 0.81
ICD and NYHA III Effect | MUSTT | 0.10 | 0.39 | 1.10 | 0.84 | 0.89 | 0.93
ICD and NYHA III Effect | SCD-HeFT | 0.58 | 0.86 | 1.31 | 0.16 | 0.37 | 0.58
ICD and NYHA III Effect | Overall | 0.26 | 0.58 | 1.33 | 0.68 | 0.80 | 0.87
ICD and NYHA IV Effect | AVID | 0.04 | 0.86 | 14.52 | 0.42 | 0.46 | 0.51
ICD and NYHA IV Effect | CABG-PATCH | 0.20 | 0.70 | 2.06 | 0.50 | 0.58 | 0.66
ICD and NYHA IV Effect | CASH | 0.02 | 0.52 | 10.66 | 0.59 | 0.63 | 0.66
ICD and NYHA IV Effect | DEFINITE | 0.05 | 0.88 | 12.87 | 0.42 | 0.46 | 0.51
ICD and NYHA IV Effect | MADIT-I | 0.05 | 0.66 | 12.46 | 0.52 | 0.56 | 0.59
ICD and NYHA IV Effect | MADIT-II | 0.49 | 1.58 | 5.10 | 0.12 | 0.16 | 0.21
ICD and NYHA IV Effect | MUSTT | 0.06 | 0.86 | 16.81 | 0.42 | 0.47 | 0.52
ICD and NYHA IV Effect | SCD-HeFT | 0.06 | 1.03 | 20.10 | 0.37 | 0.41 | 0.46
ICD and NYHA IV Effect | Overall | 0.21 | 0.81 | 3.17 | 0.41 | 0.49 | 0.56
ICD and Ischemic Effect | AVID | 0.36 | 0.62 | 1.09 | 0.66 | 0.82 | 0.90
ICD and Ischemic Effect | CABG-PATCH | 0.52 | 0.82 | 1.27 | 0.26 | 0.46 | 0.65
ICD and Ischemic Effect | CASH | 0.19 | 0.48 | 1.08 | 0.80 | 0.87 | 0.93
ICD and Ischemic Effect | DEFINITE | 0.12 | 0.67 | 3.42 | 0.53 | 0.61 | 0.67
ICD and Ischemic Effect | MADIT-I | 0.16 | 0.37 | 0.91 | 0.91 | 0.95 | 0.97
ICD and Ischemic Effect | MADIT-II | 0.40 | 0.70 | 1.25 | 0.49 | 0.70 | 0.82
ICD and Ischemic Effect | MUSTT | 0.28 | 0.64 | 1.41 | 0.60 | 0.73 | 0.81
ICD and Ischemic Effect | SCD-HeFT | 0.36 | 0.76 | 1.51 | 0.45 | 0.52 | 0.61
ICD and Ischemic Effect | Overall | 0.31 | 0.63 | 1.30 | 0.63 | 0.75 | 0.85

Abbreviations for Table 8: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; HR = hazard ratio; ICD = implantable cardioverter defibrillator; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Table 9 Hazard ratios for the effect of treatment given 48 subgroups of prognostic variables

Sub- group | Age Group | EF | NYHA | Isch/ Non- Isch | Control | | ICD | | Hazard Ratio | | | Probability HR ≤ 0.70 | Probability HR ≤ 0.80 | Probability HR ≤ 0.90
Sub- group | Age Group | EF | NYHA | Isch/ Non- Isch | #Sub- jects | # Events | #Sub- jects | # Events | Lower | Median | Upper | Probability HR ≤ 0.70 | Probability HR ≤ 0.80 | Probability HR ≤ 0.90
1 | < 65 | <30% | I | Non-Isch | 45 | 9 | 42 | 3 | 0.34 | 0.60 | 1.13 | 0.69 | 0.83 | 0.90
2 | < 65 | <30% | I | Isch | 247 | 39 | 295 | 28 | 0.31 | 0.63 | 1.30 | 0.63 | 0.75 | 0.85
3 | < 65 | <30% | II | Non-Isch | 240 | 33 | 227 | 24 | 0.24 | 0.55 | 1.24 | 0.72 | 0.82 | 0.88
4 | < 65 | <30% | II | Isch | 306 | 96 | 302 | 40 | 0.23 | 0.58 | 1.35 | 0.67 | 0.78 | 0.86
5 | < 65 | <30% | III | Non-Isch | 92 | 21 | 82 | 17 | 0.26 | 0.58 | 1.33 | 0.68 | 0.80 | 0.87
6 | < 65 | <30% | III | Isch | 171 | 68 | 188 | 51 | 0.25 | 0.61 | 1.39 | 0.65 | 0.75 | 0.83
7 | < 65 | <30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.21 | 0.81 | 3.17 | 0.41 | 0.49 | 0.56
8 | < 65 | <30% | IV | Isch | 16 | 6 | 27 | 8 | 0.18 | 0.84 | 3.70 | 0.38 | 0.46 | 0.53
9 | < 65 | ≥30% | I | Non-Isch | 15 | 3 | 9 | 1 | 0.27 | 0.62 | 1.57 | 0.62 | 0.73 | 0.80
10 | < 65 | ≥30% | I | Isch | 173 | 15 | 156 | 10 | 0.26 | 0.65 | 1.57 | 0.57 | 0.68 | 0.77
11 | < 65 | ≥30% | II | Non-Isch | 94 | 10 | 98 | 10 | 0.20 | 0.57 | 1.56 | 0.66 | 0.74 | 0.80
12 | < 65 | ≥30% | II | Isch | 157 | 35 | 135 | 22 | 0.21 | 0.58 | 1.58 | 0.64 | 0.72 | 0.79
13 | < 65 | ≥30% | III | Non-Isch | 23 | 6 | 30 | 1 | 0.21 | 0.60 | 1.72 | 0.63 | 0.73 | 0.79
14 | < 65 | ≥30% | III | Isch | 58 | 19 | 50 | 19 | 0.21 | 0.61 | 1.76 | 0.59 | 0.69 | 0.77
15 | < 65 | ≥30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.17 | 0.85 | 3.60 | 0.38 | 0.47 | 0.54
16 | < 65 | ≥30% | IV | Isch | 2 | 0 | 6 | 1 | 0.17 | 0.91 | 3.72 | 0.36 | 0.42 | 0.49
17 | [65,75) | <30% | I | Non-Isch | 18 | 5 | 20 | 1 | 0.30 | 0.67 | 1.48 | 0.55 | 0.68 | 0.79
18 | [65,75) | <30% | I | Isch | 222 | 53 | 211 | 34 | 0.28 | 0.69 | 1.58 | 0.51 | 0.64 | 0.75
19 | [65,75) | <30% | II | Non-Isch | 74 | 14 | 78 | 14 | 0.23 | 0.61 | 1.50 | 0.63 | 0.72 | 0.81
20 | [65,75) | <30% | II | Isch | 198 | 64 | 249 | 61 | 0.23 | 0.63 | 1.58 | 0.58 | 0.70 | 0.78
21 | [65,75) | <30% | III | Non-Isch | 37 | 17 | 32 | 15 | 0.23 | 0.64 | 1.68 | 0.59 | 0.69 | 0.79
22 | [65,75) | <30% | III | Isch | 128 | 65 | 133 | 49 | 0.25 | 0.65 | 1.77 | 0.55 | 0.67 | 0.75
23 | [65,75) | <30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.21 | 0.87 | 4.25 | 0.37 | 0.45 | 0.52
24 | [65,75) | <30% | IV | Isch | 20 | 4 | 24 | 8 | 0.18 | 0.93 | 4.26 | 0.35 | 0.42 | 0.49
25 | [65,75) | ≥30% | I | Non-Isch | 4 | 3 | 3 | 0 | 0.25 | 0.67 | 1.90 | 0.52 | 0.63 | 0.71
26 | [65,75) | ≥30% | I | Isch | 98 | 17 | 101 | 16 | 0.25 | 0.69 | 2.02 | 0.51 | 0.61 | 0.69
27 | [65,75) | ≥30% | II | Non-Isch | 21 | 5 | 19 | 4 | 0.19 | 0.62 | 1.93 | 0.58 | 0.67 | 0.74
28 | [65,75) | ≥30% | II | Isch | 110 | 35 | 74 | 8 | 0.21 | 0.63 | 1.96 | 0.56 | 0.66 | 0.73
29 | [65,75) | ≥30% | III | Non-Isch | 13 | 1 | 7 | 2 | 0.19 | 0.65 | 1.93 | 0.55 | 0.64 | 0.72
30 | [65,75) | ≥30% | III | Isch | 37 | 17 | 33 | 16 | 0.21 | 0.65 | 2.13 | 0.54 | 0.63 | 0.70
31 | [65,75) | ≥30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.17 | 0.94 | 4.11 | 0.35 | 0.42 | 0.48
32 | [65,75) | ≥30% | IV | Isch | 5 | 3 | 4 | 2 | 0.18 | 0.98 | 4.42 | 0.33 | 0.40 | 0.46
33 | 75+ | <30% | I | Non-Isch | 3 | 2 | 12 | 3 | 0.24 | 0.57 | 1.31 | 0.68 | 0.78 | 0.86
34 | 75+ | <30% | I | Isch | 80 | 21 | 92 | 22 | 0.23 | 0.60 | 1.44 | 0.62 | 0.74 | 0.81
35 | 75+ | <30% | II | Non-Isch | 20 | 8 | 22 | 4 | 0.20 | 0.52 | 1.42 | 0.71 | 0.79 | 0.85
36 | 75+ | <30% | II | Isch | 77 | 28 | 76 | 16 | 0.19 | 0.54 | 1.48 | 0.68 | 0.76 | 0.83
37 | 75+ | <30% | III | Non-Isch | 5 | 4 | 16 | 3 | 0.19 | 0.54 | 1.55 | 0.69 | 0.76 | 0.81
38 | 75+ | <30% | III | Isch | 67 | 35 | 78 | 33 | 0.20 | 0.56 | 1.62 | 0.66 | 0.72 | 0.80
39 | 75+ | <30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.16 | 0.78 | 3.53 | 0.44 | 0.52 | 0.58
40 | 75+ | <30% | IV | Isch | 6 | 1 | 7 | 3 | 0.15 | 0.83 | 3.71 | 0.42 | 0.48 | 0.54
41 | 75+ | ≥30% | I | Non-Isch | 2 | 0 | 1 | 1 | 0.20 | 0.59 | 1.75 | 0.62 | 0.70 | 0.78
42 | 75+ | ≥30% | I | Isch | 42 | 8 | 43 | 7 | 0.20 | 0.60 | 1.80 | 0.61 | 0.69 | 0.75
43 | 75+ | ≥30% | II | Non-Isch | 7 | 4 | 4 | 1 | 0.16 | 0.53 | 1.65 | 0.67 | 0.75 | 0.80
44 | 75+ | ≥30% | II | Isch | 34 | 10 | 36 | 8 | 0.17 | 0.55 | 1.69 | 0.65 | 0.73 | 0.79
45 | 75+ | ≥30% | III | Non-Isch | 3 | 1 | 6 | 0 | 0.15 | 0.55 | 1.98 | 0.64 | 0.72 | 0.77
46 | 75+ | ≥30% | III | Isch | 10 | 5 | 11 | 5 | 0.16 | 0.58 | 1.99 | 0.62 | 0.69 | 0.76
47 | 75+ | ≥30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.14 | 0.82 | 3.59 | 0.41 | 0.48 | 0.56
48 | 75+ | ≥30% | IV | Isch | 0 | 0 | 0 | 0 | 0.15 | 0.87 | 3.92 | 0.40 | 0.46 | 0.52

Abbreviations for Table 9: EF = ejection fraction; HR = hazard ratio; ICD = implantable cardioverter defibrillator; Isch = ischemic; Non-Isch = non-ischemic; NYHA = New York Heart Association

While these results seem to contradict those arising from Appendix Tables A13–A21, we note that this full hierarchical model accounts for a variety of sources of variation not accounted for in the previous models; for example, that the interactions between treatment and say the presence of ischemia may not be the same across trials. But in doing so, we deal with yet another issue in that some prognostic subgroups were not observed in all trials. When accounting for all of these sources of variation, there is no longer evidential support for interactions.

Key points: Combining data from trials improves our inferences by increasing the precision of our estimates as well as the power to detect main effects and interactions. There are a variety of modeling approaches that allow us to combine data from different trials, but they do not necessarily lead to the same inference.

Understanding the underlying model assumptions and limitations is important when interpreting the results from the combined analysis. For example, in this section we observed that some models showed evidence for an interaction between treatment and AGE in the combined analysis. But this evidence arises from models that assume that this interaction is the same across all trials. If this assumption is considered unreasonable, and we consider instead a model that accounts for the variation of the interaction across trials, then the interaction between treatment and AGE is no longer significant.

Finally, when considering Bayesian estimation, the role of priors should also be examined through a sensitivity analysis. We delay the discussion on the effect of priors to the section on “Analysis of Aggregate versus Patient-level Data,” below.

### Using Registry Data

Table 10 provides descriptive characteristics of CMS ICD Registry patients (note this is limited to Medicare patients within the ACC-NCDR Registry). As compared to patients recruited to the actual ICD trials, we note that patients in the registry are older and with worse prognosis. Of particular note is that more than 87 percent of the patients in the CMS ICD Registry are NYHA Class II or greater while these patients represented approximately just two thirds of the trial patients.

Table 10 Descriptive statistics for CMS ICD registry

Characteristic | | Value
Age
Mean, years | | 72.78
Median, years | | 73.5
Standard deviation, years | | 9.89
Ejection Fraction
Mean, % | | 27.11
Median, % | | 25
Standard deviation, % | | 10.11
NYHA Class
Class I | | 13,812 (11.38 %)
Class II | | 40,441 (33.31%)
Class III | | 59,656 (49.14%)
Class IV | | 6299 (5.19%)
Ischemic Disease
Yes | | 87,055 (71.71%)
No | | 33,968 (27.98%)

Abbreviations for Table 10: CMS = Centers for Medicare & Medicaid Services; ICD = implantable cardioverter defibrillator

As we discussed before, the current CMS registry does not have survival after discharge. Thus, we utilized the registry data from the MUSTT study for illustrative purposes. Table 11 has descriptive statistics for the MUSTT registry. We note that patients in the MUSTT registry also have different characteristics from those in the CMS registry. We also note that only approximately 35 percent of the patients in the MUSTT registry received beta-adrenergic blocking agents perhaps influencing the cohort’s mortality.

Table 11 Descriptive statistics for MUSTT registry^*^

Characteristic | | Control | ICD
Number of patients | | 1414 | 84
Age | Mean (SD) | 65.1 (9.50) | 63.0 (9.20)
Age | < 65 | 607 (42.93%) | 41 (48.81%)
Age | [65,75) | 618 (43.71%) | 38 (45.24%)
Age | [75,85) | 186 (13.15%) | 5 (5.95%)
Age | ≥ 85 | 3 (0.21%) | 0
Ejection Fraction | Mean (SD) | 28 (7.90) | 27.7 (8.00)
Ejection Fraction | ≤30% | 878 (62.09%) | 55 (65.48%)
Ejection Fraction | > 30% | 536 (37.91%) | 29 (34.52%)
Ischemic Disease | Yes | 1414 (100.00%) | 84 (100.00%)
Ischemic Disease | No | 0 | 0
NYHA Class | I | 249 (36.89%) | 18 (51.43%)
NYHA Class | II | 263 (38.96%) | 13 (37.14%)
NYHA Class | III | 162 (24.00%) | 4 (11.43%)
NYHA Class | IV | 1 (0.15%) | 0

* Entries refer to means accompanied by standard deviations for continuous variables, or counts followed by percentages for categorical variables.

Abbreviations for Table 11: ICD = implantable cardioverter defibrillator; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SD = standard deviation

Figures 12(a) and 12(b) show the posterior predictive survival distribution for the ICD and control groups along with the empirical survival distribution from the registry data in two subgroups. For these subgroups, there are few patients in the MUSTT registry who received an ICD. Control patients in the MUSTT registry have better survival earlier on, but more comparable (to the posterior predictive survival) in later years.

Figure 12 (a) Posterior predictive survival distributions under the ICD and control group for hypothetical patients with age [65,75), ejection fraction < 30%, NYHA II and ischemic disease and empirical survival distribution from corresponding registry patients in the MUSTT registry

Figure 12 (b) Posterior predictive survival distributions under the ICD and control group (for hypothetical patients with age 75+, ejection fraction < 30%, NYHA II and ischemic disease and empirical survival distribution from corresponding registry patients in the MUSTT registry

Key points: The above analysis illustrates that we can utilize Bayesian hierarchical models to predict survival from patients in subgroups. This was an illustration and not a definitive examination of the strengths and weaknesses of the Bayesian approach to this problem. Indeed, in this data set we observed that the predictions from the Bayesian model were not always consistent with the survival observed in the registry. Various interpretations of this observation are possible, among them being the possibility (independent of the particular statistical model being employed) that patients in the registry had a different prognosis than patients in the clinical trials.

### Analysis of Aggregate versus Patient-level Data

Appendix Figure A5(a) (see also Appendix Table A28) shows the results from the analysis that combines aggregate data sequentially mimicking when the trials were completed and their data available. Trials were combined in the following order (based on their publication date): MADIT-I, AVID, CABG-PATCH, MUSTT, CASH, MADIT-II, DEFINITE, SCD-HeFT.

As we accumulate data from trials, the 95 percent posterior credible intervals under both priors get narrower. The gain of information with accumulated data is greater under the less informative prior. We demonstrate how under two priors, upon combining aggregate data from all trials, we can find only a borderline evidence of overall ICD efficacy under one prior, while we do not rule out no efficacy under the alternative prior.

In contrast, Appendix Figure A5(b) (see also Appendix Table A29) shows the results from the analysis that combines patient-level data sequentially. As we combine data from more trials, the estimates become more similar and precise. Using the more informative prior we would have concluded overall ICD efficacy sooner with six trials.

Key points: In this section we examined the use of patient-level data versus aggregate data as information accrues over time. Our analysis showed that the resulting inferences are not necessarily the same. The analysis of aggregate data may be more sensitive to priors.

Finally, we note that the above analysis which assesses the interactions between treatment and covariates defining the subgroups of interest may not be feasible with aggregate data (see Pocock et al.26 for a review on issues with published subgroup analysis).

We now further examine the Bayesian hierarchical model that combines patient-level data from all eight trials. In what follows we will state a sample of questions of clinical interest that we can examine with this model.

Question 1: Is there evidence that the devices used in the different trials differ in terms of their efficacies?

Answer: As we have discussed before, the Bayesian hierarchical model accounts for the variability within and between trials. In particular, we assume that ICD efficacy is trial-specific, but allow for the borrowing of information about ICD efficacy across trials. Figure 13 shows the estimates of treatment effect for each trial and the overall effect across all trials. There is evidence that treatment efficacy differs across trials. Why this is the case is uncertain. The differences in treatment efficacy could be due to differences in the devices used in the trials, but they could also be due to the patient population being different across trials – even after controlling for age, EF, NYHA class, and ischemia. For example, additional information concerning the QRS interval, gender, or time from myocardial infarction could explain the differences in ICD efficacy. Accounting for these differences, under prior 1 we estimate that the hazard of death in the ICD group is exp(−0.43) = 0.65 times the hazard in the control group. The 95 percent posterior credible interval is 0.41 to 1.02. Under prior 2 we estimate the hazard of death in the ICD group is 0.66 times that in the control group, with a 95 percent posterior credible interval of 0.49 to 0.90. That is, under the more informative prior 2, our analysis supports the evidence of overall ICD efficacy across all trials. (Note that the two priors used above represent beliefs of no treatment effect. Both priors are centered around no treatment effect. We describe prior 2 as being more informative in the sense that it places heavier mass around no treatment effect).

Question 2: Controlling for EF, ischemia, age, and NYHA class, are patients within the available trials similar?

Answer: Another feature of our Bayesian hierarchical model is that it allows for the baseline survival functions to vary from trial-to-trial. Figure 14 shows the estimated posterior baseline survival functions under each trial and overall trials. Even controlling for EF, ischemia, age, and NYHA class, the figure indicates that patients’ survival differs within the available trials. Patients in the SCD-HeFT trial seem to have the best survival prognosis. Patients in CABG-PATCH, AVID and MUSTT have poorer survival prognosis. Again, as discussed under Question 1, there are several potential explanations for this difference. The variation across trials could be due to differences in the implanted devices, in the underlying medical care of the patient populations, or in patient characteristics that are currently not included in our analysis (e.g., gender, QRS interval, time from myocardial infarction). To gain further insight into these differences, additional patient-level data would be required from the trials, and the Bayesian hierarchical model would need to be updated to reflect this additional knowledge. Our group currently has a research grant starting 12/1/09 to gain access to these needed data and to update our Bayesian model so as to allow exploration of these described differences.

Also note that the variation across trials could be due in part to the fact that some of our trials were secondary prevention trials (CASH, AVID), while the remaining trials were primary prevention trials. As we described earlier, we chose to combine data from all ICD trials and explored the effects of the four prognostic characteristics across these populations. However, to explore the potential impact of a patient having previously experienced a sudden cardiac arrest, we performed additional sensitivity analyses to assess whether treatment may have a different effect in the primary versus secondary patient populations. These analyses and their findings are detailed in the Appendix (see the discussion of Question 2 under “Analysis of Aggregate versus Patient-level Data”, “Key points”, and Appendix Tables A31 and A32). They demonstrate that even though the patient populations may be different, there is no evidence for differences in treatment effect. This supports our approach, which combined data from all trials.

Question 3: Is there evidence that the ICD has different effects across patient subgroups?

Answer: The Bayesian hierarchical model also allows for trial-specific interactions. From our analysis [see Appendix Table A30], there was no evidence for overall interactions between treatment and the covariates that define the subgroups of interest. In other words, there was no evidence for treatment-covariate interaction across prognostic subgroups. We again direct the reader to Tables 8 and 9 for easier interpretation of these results. Table 8 provides the median hazard ratios and the 95 percent credible intervals for the effect of treatment within the main subgroups defined by the prognostic variables for the individual trials and then for the entire population of trials. We also provide the posterior probability that the hazard ratio for the total mortality reduction from the ICD treatment would be 0.80 or less, as this was considered a clinically important reduction in mortality by our technical expert panel. For sensitivity analysis, we also present probabilities when using different clinical cutoffs, that is, of 0.70 and 0.90. So, for example, although the 95 percent credible interval for the overall hazard ratio for the reduction in mortality from ICD implant includes the value of no treatment efficacy (that is, a hazard ratio equal to 1), with 83 percent posterior probability the hazard ratio is 0.80 or less, indicating a clinically significant reduction. However, if we consider the findings for treatment and NHYA class IV patients, we observe that not only is there no evidence of a significant interaction, but there is only a 49 percent probability that the hazard ratio is 0.80 or less. Table 8 shows that the data from the combined trials do not demonstrate a significant treatment effect given the main prognostic variables. Similarly, in Table 9, we provide the same information (median hazard ratios, 95 percent credible intervals, and posterior probability that the hazard ratio is less or equal to 0.70, 0.80, and 0.90) for each of the 48 subgroups. Again, note that there is no evidence of treatment benefit in the individual subgroups. The probability that the hazard ratio is 0.80 or less is, however, at least 75 percent in 11 of the subgroups indicated in red in the table.

Figure 13 Posterior estimates (mean along with 95% posterior credible intervals) for the overall treatment effect under two priors (prior 2 is more informative than prior 1)

Figure 14 Estimated posterior baseline survival functions

## Methodological and Clinical Implications of Findings

This case study illustrates Situations 1, 2, and 3 (described under CMS contexts). For example, corresponding to Situation 1, in the CASH trial there was no overall efficacy of the ICD, but with a naïve analysis one could find efficacy within the subgroup with patients < 65 years old, ≤ 30 percent, NYHA Class II and ischemic disease. Illustrating Situation 2, the AVID trial supports overall efficacy of the device. However, concern may be raised in the subgroup of patients with < 65 years old, ≤ 30 percent, NYHA Class III and ischemic disease, even though the survival comparison within the subgroup was not significant. Finally, illustrating Situation 3, some trials do not have all subgroups represented. For example, the DEFINITE trial was only on non-ischemic patients.

Regarding Situations 1 and 2, testing for interactions at the individual trials often did not support the presence of treatment-covariate interactions. Combining data from the trials improves the power to detect interactions. However, in this case study, the analysis that combined data from the trials generally did not support the presence of interactions. Such conclusions are supported under different model formulations as well as different estimation approaches. In particular, we note that our Bayesian estimation of the models that combined data from trials gave similar estimates to those obtained under the classical frequentist approaches. This illustrates that for large studies, Bayesian inferences are less sensitive to prior choices.

Utilizing the full Bayesian hierarchical model, we simulated the survival experience of hypothetical patients in a new clinical trial. This accounts for both, the variation between and within clinical trials. Because of the borrowing of information across trials, this model allows us to predict survival even if an individual trial does not include some of the subgroups (thus, addressing Situation 3). Using this approach, we note that the survival in the registry data is better (relative to those predicted by our model) in early years. We note, however, that such analysis has an exploratory feature as confounding might be present. We also note that this model could not be estimated using classical frequentist approaches.

Finally, we note that the individual ICD studies were challenging to interpret when considered in isolation because of sample size, inconsistent statistical significance, and inconsistent subgroup effects. This is just the circumstance that Bayesian methods work well and, indeed, when the studies were considered together in a Bayesian context ("borrowing strength" from other studies and other subgroups), the results were much more consistent.