# Clinical Domain: The Implantable Cardioverter Defibrillator for the Prevention of Sudden Cardiac Death

## Introduction

To explore the use of Bayesian techniques in the CMS context we evaluate the use of the implantable cardioverter defibrillator (ICD) in the prevention of sudden cardiac death. This domain is of particular interest as it represents:

- A clinical domain and intervention which CMS has evaluated and for which it has provided coverage decisions several times over the past two decades.
- An intervention which has been demonstrated to be effective in specific trial populations, but for which there is uncertainty in particular subgroups,
- A costly intervention to the Medicare program.
- A domain where there have been numerous clinical trials evaluating the ICD in diverse populations.
- An intervention for which CMS has issued a “Coverage with Evidence Development” requirement, thereby establishing with professional societies an ICD registry to monitor the use of the ICD outside the confines of the clinical trials.
- Several clinical and policy questions remain regarding the optimal use of the ICD.

Put in terms of the criteria recommended in the tutorial, the use of ICDs is a potential application of Bayesian methods because (a) CMS is particularly interested in the use of ICDs for subgroups of patients, such as those aged 65 years and above and those at highest risk for sudden cardiac death; (b) the information for some of these subgroups is inconclusive, due to small sample sizes (i.e., thus satisfying the condition of “some but not quite enough data”); and (c) other information – for example, data from other subgroups – is available. ICDs have been subjected to multiple randomized trials, with results that are not entirely consistent, especially when specific subgroups are considered in isolation. Thus, Bayesian methods might be used to “gain strength” by combining data both within and across studies, and also to resolve some of the apparent inconsistencies in our knowledge about ICDs.

This chapter provides basic clinical background about sudden cardiac death; ICDs; the trials; current CMS coverage decisions; other information that might be brought to bear on decisions about ICDs, such as registries; and a translation of CMS’ decisional context into the terminology of this report. The following chapter will take the background of this case study as given, and explore some of the statistical properties of the application of Bayesian methods to the case study.

## Sudden Cardiac Death

Sudden cardiac death (SCD), usually due to a ventricular tachyarrhythmia (rapid abnormal heart beat), is the most common cause of death in the United States accounting for up to 350,000 deaths per year.46 Each year, SCD claims more lives than stroke, lung cancer, breast cancer, and AIDS combined. Although the overall number of cardiac deaths has decreased over the past decade, the proportion of cardiac deaths that are sudden has increased. This increase in the rate of SCD has resulted from our inability to accurately identify those who will die suddenly and to improve the utilization of therapies that have been proven to reduce the risk of SCD in certain patient populations.

## The Implantable Cardioverter Defibrillator

The ICD is a device that monitors heart rhythms and delivers shocks if dangerous rhythms are detected. Like a pacemaker, an ICD consists of a battery and pulse generator connected to one or more insulated wires or leads. This generator and batteries are sealed together and implanted under the skin of a patient at risk for sudden cardiac death, usually near the patient’s shoulder. The leads are threaded through the blood vessels from the ICD to the heart muscle. Once inserted, the ICD continuously checks the heart rate, and when it detects a too-rapid or irregular heartbeat, it delivers a shock that aims to reset the heart to a more normal rate and electrical pattern.

Recent clinical trials of patients considered at risk for sudden cardiac death have demonstrated that the ICD is the most effective therapy currently available for the prevention of sudden cardiac death.47–56 Although the overall mortality benefit from ICD therapy is evident, the magnitude of effectiveness of ICD therapy in clinically defined subgroups is unclear. In addition, given the substantial cost associated with ICD implantation and followup, the clinical and policy community currently are exploring methods of aiding in risk stratification for at-risk populations to increase the potential benefit of the ICD.

## Current ICD Clinical Trials and Evidence of Efficacy

Following the introduction of the ICD, there have been numerous clinical trials evaluating its efficacy in various at-risk populations. The earliest trials evaluated the ICD in patients who had survived a previous sudden cardiac arrest or who presented with sustained ventricular tachycardia or syncope. These trials included the Canadian Implantable Defibrillator Study (CIDS), the Antiarrhythmics Versus Implantable Defibrillators (AVID) trial, and the Cardiac Arrest Study Hamburg (CASH) trial. Although the ICD was shown to be effective in this high-risk population, most patients who suffer sudden cardiac arrest do not survive this initial event. Therefore subsequent trials sought to identify patients who although not survivors of a previous sudden cardiac arrest, were at a risk for sudden cardiac death high enough to benefit from ICD therapy. These trials included the two Multicenter Automatic Defibrillator Implantation Trials (MADIT-I and MADIT-II), the Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation (DEFINITE) trial, the Multicenter Unsustained Tachycardiac Trial (MUSTT), Defibrillator in Acute Myocardial Infarction Trial (DINAMIT), Coronary Artery Bypass Graft Patch trial (CABG-PATCH), and the largest trial being the Sudden Cardiac Death in Heart Failure Trial (SCD-HeFT).

Table 2 lists the current ICD trials and their timings. The primary and secondary prevention trials are sorted within the table by publication date to indicate when the results of the trials became publicly available and could potentially have been used for designing future trials, or stopping ongoing trials. Those trials marked with an asterisk indicate that their patient-level data are included in our case study analysis.

Table 2 Patient recruitment and followup timing in ICD primary and secondary prevention trials^†^

Trial | 87 + | 90 | 91 | 92 | 93 | 94 | 94 | 96 | 97 | 98 | 99 | 00 | 01 | 02 | 03 | Pub Date
MADIT-I^*^ | | | | | | | | | | | | | | | | 12/26/1996
AVID^*^ | | | | | | | | | | | | | | | | 11/27/1997
CABG-PATCH^*^ | | | | | | | | | | | | | | | | 12/27/1997
MUSTT^*^ | | | | | | | | | | | | | | | | 12/16/1999
CIDS | | | | | | | | | | | | | | | | 3/21/2000
CASH^*^ | | | | | | | | | | | | | | | | 8/15/2000
MADIT-II^*^ | | | | | | | | | | | | | | | | 3/21/2002
DEFINITE^*^ | | | | | | | | | | | | | | | | 5/20/2004
DINAMIT | | | | | | | | | | | | | | | | 12/9/2004
SCD-HeFT^*^ | | | | | | | | | | | | | | | | 1/20/2005

† Shaded areas indicate those years during which the given trial was recruiting and following patients. Trials shaded in black are considered primary prevention trials; those in gray are considered secondary prevention trials. The date of publication of the main trial results are listed in the final column.

* Indicates that patient-level data from the trial are included in the case study analysis.

Abbreviations for Table 2: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; CIDS = Canadian Implantable Defibrillator Study; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; DINAMIT = Defibrillator in Acute Myocardial Infarction Trial; ICD = Implantable cardioverter defibrillator; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Table 3 lists the patient inclusion and exclusion criteria for the different trials, the number of patients randomized to ICD therapy and control, and the efficacy of the ICD in reducing total mortality as reported in the main trial publication. Additional details regarding the distribution of patient characteristics are provided in Table 4 (Parts 1 and 2) in the ICD case study. The primary endpoint in almost all trials was total mortality (the exception being the MUSTT trial where although total mortality was reported, the primary endpoint was arrhythmic mortality or cardiac arrest). Secondary endpoints included various outcomes such as arrhythmic mortality, non-arrhythmic mortality, cardiac hospitalizations, costs, and quality of life. The main clinical characteristics which defined the patient populations included in the trials, or which were the focus of pre-defined subgroup analyses included: left ventricular ejection fraction (LVEF), QRS interval, New York Heart Association (NYHA) class, presence or absence of ischemia, and age of the patient.

Table 3 ICD clinical trial characteristics

Trial | Inclusion Criteria | Exclusion Criteria | Number of Patients | | Hazard Ratio for Death (95% CI)
Trial | Inclusion Criteria | Exclusion Criteria | ICD | Control | Hazard Ratio for Death (95% CI)
MADIT-I^*^ | MI 3 weeks or more before study; unsustained VT; EF ≤ 35% | Indication for ICD, NYHA class IV, coronary revascularization within 3 months | 95 | 101 | 0.46 (0.26 to 0.82)
AVID^*^ | Resuscitated from near-fatal ventricular fibrillation, sustained ventricular tachycardia with syncope, or sustained ventricular tachycardia with EF ≤ 40% | NYHA class IV, EF ≥ 40% | 507 | 509 | 0.62 (0.47 to 0.81)
CABG-PATCH^*^ | Scheduled for CABG, EF ≤ 35%, abnormalities on SAECG | History of sustained VT or VF | 446 | 454 | 1.07 (0.81 to 1.42)
MUSTT^*^ | CAD, EF ≤ 40%, asymptomatic non-sustained VT within 6 months and not within 4 days after an MI or CABG | History of syncope or sustained VT or VF more than 48 hours after an MI, recent CABG or PTCA, NYHA IV symptoms | 161 | 353 | 0.45 (0.32 to 0.63)
CIDS | Documented VF; out-of-hospital cardiac arrest requiring defibrillation or cardioversion; documented, sustained VT causing syncope; other documented, sustained VT at a rate ≥ 150 beats/min, causing presyncope or angina in a patient with a left ventricular EF ≤ 35% | ICD or amiodarone not considered appropriate as a treatment for the tachyarrhythmia, excessive perioperative risk for ICD implantation; previous amiodarone therapy for ≥ 6 weeks; non-arrhythmic medical condition making 1-year survival unlikely, or long-QT syndrome | 328 | 331 | 0.82 (0.60 to 1.1)
CASH^*^ | Resuscitated from cardiac arrest secondary to documented sustained ventricular arrhythmias | Cardiac arrest occurred within 72 hours of an acute MI, cardiac surgery, electrolyte abnormalities, or proarrhythmic drug effect | 99 | 189 | 0.766 (upper bound 1.112)
MADIT-II^*^ | MI 1 month or more before study; EF ≤ 30% | Indication for ICD, NYHA class IV, coronary revascularization within 3 months, MI within 1 month | 742 | 490 | 0.69 (0.51 to 0.93)
DEFINITE^*^ | EF ≤ 35%, ambient arrhythmias, symptomatic heart failure, presence of non-ischemic cardiomyopathy | NYHA class IV, non-ICD candidates, undergone EP testing within 3 months prior or had permanent pacemakers | 229 | 229 | 0.65 (0.40 to 1.06)
DINAMIT | Within 4 to 40 days of an MI, EF ≤ 35%, impaired autonomic tone by heart rate variability | NYHA class IV symptoms, CABG done since the qualifying MI or planned to be done within 4 weeks, 3-vessel PTCA since qualifying infarct, on heart transplant list | 332 | 342 | 1.08 (0.76 to 1.55)
SCD-HeFT^*^ | NYHA class II or III symptoms, EF ≤ 35% and on optimal medical therapy | NYHA IV symptoms, a history of cardiac arrest or spontaneous sustained VT not associated with an MI | 829 | 847 | 0.77 (0.62 to 0.96)

* Indicates that patient-level data from the trial are included in the case study analysis.

Abbreviations for Table 3: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG = coronary artery bypass graft; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CAD = coronary artery disease; CASH = Cardiac Arrest Study Hamburg trial; CI = confidence interval; CIDS = Canadian Implantable Defibrillator Study; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; DINAMIT = Defibrillator in Acute Myocardial Infarction Trial; EF = ejection fraction; EP = electrophysiology; ICD = implantable cardioverter defibrillator; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MI = myocardial infarction; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; PTCA = percutaneous transluminal coronary angioplasty; SAECG = signal averaging electrocardiogram; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; VF = ventricular fibrillation; VT = ventricular tachycardia

Table 4 – Part 1 Descriptive statistics for prognostic variables stratified by trial and treatment groups (AVID, CABG-PATCH, CASH, and DEFINITE)^*^

Characteristic | | AVID | | CABG-PATCH | | CASH | | DEFINITE
Characteristic | | Control | ICD | Control | ICD | Control | ICD | Control | ICD
Number of Patients | | 509 | 507 | 454 | 446 | 189 | 99 | 229 | 229
Age | Mean (SD) | 65.33 (10.19) | 64.83 (10.82) | 64.95 (9.39) | 64.07 (9.21) | 57.83 (10.59) | 57.46 (11.18) | 58.11 (11.96) | 58.41 (13.84)
Age | < 65 | 215 (42.24%) | 229 (45.17%) | 227 (50.00%) | 223 (50.00%) | 145 (76.72%) | 72 (72.73%) | 153 (66.81%) | 148 (64.63%)
Age | [65,75) | 203 (39.88%) | 185 (36.49%) | 174 (38.33%) | 168 (37.67%) | 37 (19.58%) | 25 (25.25%) | 63 (27.51%) | 51 (22.27%)
Age | [75,85) | 86 (16.90% | 85 (16.77%) | 53 (11.67%) | 55 (12.33%) | 6 (3.17%) | 2 (2.02%) | 13 (5.68%) | 30 (13.10%)
Age | ≥ 85 | 5 (00.98%) | 8 (1.58%) | 0 | 0 | 1 (0.53%) | 0 | 0 | 0
Ejection Fraction | Mean (SD) | 30.82 (13.24) | 32.15 (13.46) | 27.05 (5.82) | 27.13 (5.75) | 45.18 (17.21) | 45.89 (19.51) | 21.84 (6.08) | 20.88 (5.93)
Ejection Fraction | ≤ 30% | 294 (58.22%) | 273 (54.17%) | 323 (71.15%) | 317 (71.08%) | 35 (20.47%) | 23 (24.21%) | 215 (93.89%) | 219 (95.63%)
Ejection Fraction | > 30% | 211 (32.76%) | 231 (45.83%) | 131 (28.85%) | 129 (28.92%) | 136 (79.53%) | 72 (75.79%) | 14 (6.11%) | 10 (4.37%)
Ischemic Disease | Yes | 433 (85.07%) | 435 (85.80%) | 454 (100.00%) | 446 (100.00%) | 167 (88.83%) | 88 (88.89%) | 0 | 0
Ischemic Disease | No | 76 (14.93%) | 72 (14.20%) | 0 | 0 | 21 (11.17%) | 11 (11.11%) | 229 (100.00%) | 229 (100.00%)
NYHA Class | I | 313 (61.49%) | 329 (64.89%) | 258 (56.95%) | 247 (55.88%) | 54 (29.35%) | 24 (24.49%) | 41 (17.90%) | 58 (25.33%)
NYHA Class | II | 136 (26.72%) | 144 (28.40%) | 85 (18.76%) | 87 (19.68%) | 106 (57.61%) | 56 (57.14%) | 139 (60.70%) | 124 (54.15%)
NYHA Class | III | 60 (11.79%) | 34 (6.71%) | 81 (17.88%) | 73 (16.52%) | 24 (13.04%) | 18 (18.37%) | 49 (21.40%) | 47 (20.52%)
NYHA Class | IV | 0 | 0 | 29 (6.40%) | 35 (7.92%) | 0 | 0 | 0 | 0

* Entries refer to means accompanied by standard deviations for continuous variables, or counts followed by percentages for categorical variables.

Abbreviations to Table 4 – Parts 1 and 2: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; ICD = implantable cardioverter defibrillator; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; SD = standard deviation

Table 4 – Part 2 Descriptive statistics for prognostic variables stratified by trial and treatment groups (MADIT-I, MADIT-II, MUSTT, and SCD-HeFT)^*^

Characteristic | | MADIT-I | | MADIT-II | | MUSTT | | SCD-HeFT
Characteristic | | Control | ICD | Control | ICD | Control | ICD | Control | ICD
Number of Patients | | 101 | 95 | 490 | 742 | 353 | 167 | 847 | 829
Age | Mean (SD) | 63.8 (8.82) | 62.12 (8.73) | 64.57 (10.32) | 64.45 (10.45) | 64.87 (9.65) | 65.42 (8.52) | 58.58 (11.92) | 59.41 (11.87)
Age | < 65 | 49 (48.51%) | 53 (55.79%) | 228 (46.53%) | 345 (46.50%) | 162 (45.89%) | 72 (43.11%) | 563 (66.47%) | 535 (64.54%)
Age | [65,75) | 40 (39.60%) | 36 (37.89%) | 186 (37.96%) | 269 (36.25%) | 139 (39.38%) | 77 (46.11%) | 216 (25.50%) | 215 (25.93%)
Age | [75,85) | 12 (11.88%) | 6 (6.32%) | 69 (14.08%) | 123 (16.58%) | 50 (14.16%) | 18 (10.78%) | 64 (7.56%) | 76 (9.17%)
Age | ≥ 85 | 0 | 0 | 7 (1.43%) | 5 (0.67%) | 2 (0.57%) | 0 | 4 (0.47%) | 3 (0.36%)
Ejection Fraction | Mean (SD) | 24.57 (6.67) | 26.66 (6.50) | 23.16 (5.49) | 23.17 (5.42) | 27.65 (7.64) | 27.72 (7.91) | 25.71 (12.51) | 24.96 (12.76)
Ejection Fraction | ≤ 30% | 84 (83.17%) | 66 (69.47%) | 488 (99.59%) | 742 (100.00%) | 229 (64.87%) | 109 (65.27%) | 513 (60.57%) | 509 (61.40%)
Ejection Fraction | > 30% | 17 (16.83%) | 29 (30.53%) | 2 (0.41%) | 0 (0%) | 124 (35.13%) | 58 (34.73%) | 334 (39.43%) | 320 (38.60%)
Ischemic Disease | Yes | 101 (100.00%) | 95 (100.00%) | 490 (100.00%) | 742 (100.00%) | 353 (100.00%) | 167 (100.00%) | 453 (53.48%) | 431 (51.99%)
Ischemic Disease | No | 0 | 0 | 0 | 0 | 0 | 0 | 394 (46.52%) | 398 (48.01%)
NYHA Class | I | 33 (32.67%) | 36 (37.89%) | 187 (38.80%) | 256 (34.83%) | 71 (36.41%) | 38 (34.55%) | 0 | 0
NYHA Class | II | 50 (49.50%) | 44 (46.32%) | 165 (34.23%) | 259 (35.24%) | 75 (38.46%) | 43 (39.09%) | 594 (70.13%) | 566 (68.28%)
NYHA Class | III | 18 (17.82%) | 15 (15.79%) | 110 (22.82%) | 187 (25.44%) | 49 (25.13%) | 29 (29.36%) | 253 (29.87%) | 263 (31.72%)
NYHA Class | IV | 0 | 0 | 20 (4.15%) | 33 (4.49%) | 0 | 0 | 0 | 0

* Entries refer to means accompanied by standard deviations for continuous variables, or counts followed by percentages for categorical variables.

Abbreviations to Table 4 – Parts 1 and 2: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; ICD = implantable cardioverter defibrillator; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; SD = standard deviation

## Current Clinical Practice Guidelines for ICD Implantation

The American College of Cardiology (ACC), American Heart Association (AHA), and the Heart Rhythm Society (HRS) recently updated their guidelines for the implantation of cardiac pacemakers and antiarrhythmia devices.57 This revision updates previous versions published in 1984, 1991, 1998, and 2002. The most recent revision includes evidence from all of the clinical trials included in our case study. In the guideline, Class I recommendations are those whether the benefit is greater than the risk and implantation of an ICD is recommended.

For secondary prevention of SCD and ventricular arrhythmias, the ACC/AHA/NASPE 2008 guidelines list the following Class I indications for ICD therapy:

1. Cardiac arrest due to ventricular fibrillation (VF) or hemodynamically unstable sustained ventricular tachycardia (VT) after exclusion of any completely reversible causes.
2. Spontaneous sustained VT in association with structural heart disease.
3. Syncope of undetermined origin with clinically relevant, hemodynamically significant sustained VT or VF induced at electrophysiologic study (EPS).
4. Spontaneous sustained VT in patients without structural heart disease and not amenable to other treatments.

For the primary prevention of SCD, according to the Class I recommendations in the 2008 guidelines for ICD therapy, patients with ischemic cardiomyopathy with an LVEF < 30 percent should be considered for an ICD regardless of their NYHA class. Patients with ischemic cardiomyopathy and a LVEF > 30 percent but ≤ 35 percent should be considered for an ICD if they have NYHA Class II or III heart failure symptoms. For both indications, patients must be at least 40 days post-myocardial infarction (MI) and > 3 months post-revascularization. In addition, the new Class I recommendations for ICD therapy now include patients with non-ischemic dilated cardiomyopathy and an LVEF ≤ 35 percent who have NYHA Class II or III heart failure. Note that all recommendations apply only to patients who are receiving optimal medical therapy and have reasonable expectation of survival with good functional capacity for more than 1 year.

## Current CMS Coverage of ICD Implantation

Along with the professional societies and their assessment of the evidence regarding the ICD’s efficacy in prevention of sudden cardiac death, CMS has also reviewed the evidence several times and modified their coverage decision regarding ICDs. CMS first issued a Medicare National Coverage Determination in 1986 providing limited coverage of ICDs. The policy has expanded over the years with revisions in 1991, 1999, 2003, and most recently 2005. Each of these revisions has been prompted by the publication of new evidence regarding the efficacy of the ICD in different patient populations. The most recent coverage includes the following covered indications:

1. Documented episode of cardiac arrest due to ventricular fibrillation (VF), not due to a transient or reversible cause (effective July 1, 1991).
2. Documented sustained ventricular tachyarrhythmia (VT), either spontaneous or induced by an electrophysiology (EP) study, not associated with an acute myocardial infarction (MI) and not due to a transient or reversible cause (effective July 1, 1999).
3. Documented familial or inherited conditions with a high risk of life-threatening VT, such as long QT syndrome or hypertrophic cardiomyopathy (effective July 1, 1999).
4. Patients with ischemic dilated cardiomyopathy (IDCM), documented prior myocardial infarction (MI), NYHA Class II and III heart failure, and measured left ventricular ejection fraction (LVEF) < 35 percent.
5. Patients with non-ischemic dilated cardiomyopathy (NIDCM) > 9 months, NYHA Class II and III heart failure, and measured LVEF < 35 percent;
6. Patients who meet all current CMS coverage requirements for a cardiac resynchronization therapy (CRT) device and have NYHA Class IV heart failure.

For patients in groups 4 to 6 the following criteria must also be met:

1. Patients must not have had a coronary artery bypass graft (CABG) or percutaneous transluminal coronary angioplasty (PTCA) within the past 3 months.
2. Patients must not have had an acute MI within the past 40 days.
3. Patients must be enrolled in either an FDA-approved clinical trial or a qualified data collection system.

## ACC-NCDR^®^ ICD Registry

CMS’ objective when it required patients receiving ICDs under its 2006 NCD to be enrolled in a registry was to determine if use of ICD therapy in the primary prevention of SCD is appropriate for the Medicare beneficiaries who meet the clinical conditions in the agency’s National Coverage Decision of January 2005. CMS approved the ACC-NCDR^®^, which was already operating a registry for diagnostic catheterizations and/or coronary interventions in the cardiac catheterization lab to enroll ICD patients.

As of June 2008, the registry had collected data from 1510 hospitals totaling over 280,000 implants.58 Approximately 10,000 implants are entered into the registry per month. Although the registry is required for primary prevention patients potentially eligible for Medicare, 88 percent of implants are being done in hospitals entering all patients who are receiving ICDs. The registry data collection process collects over 130 data elements at the time of initial ICD implant, device upgrade, and device replacement.59

## Current Clinical and Policy Questions Regarding ICD Implantation

Clinically there are numerous unanswered questions related to ICDs and the prevention of sudden cardiac death. It is hoped that many of these questions will be explored through the use of the ICD registry. Answering other questions will require new clinical trials, and others may be evaluated through the combination of existing data sources. Some of the questions that device makers, professional societies, researchers, providers, and policymakers are exploring include:

- Can risk stratification techniques be used to either rule in “low-risk” patients, or rule out current “high-risk” patients?
- Can we ethically randomize future patients to “no ICD” to find more effective (or cost effective) populations?
- Will the clinical trial results be replicated in the community?
- Are the devices and medical therapies in the existing trials similar enough to allow combining data among trials?
- Can the results of the existing trials be extended to Medicare patients when the vast majority of patients within the trials were under 75 years of age?
- Can trial results be extended to populations not well represented in the existing trials (e.g., those patients with chronic kidney disease)?
- Can the ICD registry be used to answer questions about subgroups of uncertain efficacy in the trials?

We next explore how these questions and past research provide examples of CMS decisional contexts.

## CMS Contexts

The clinical domain of the prevention of sudden cardiac death and the existing clinical trials which have evaluated the use of the ICD in populations at risk for sudden death provide illustrative examples of each of the four CMS decisional contexts we used to frame this project. We detail here either existing or potential examples of these four situations.

Situation 1: Applicants present CMS with results that suggest none or minimal efficacy of an intervention for the overall population, but apparent effectiveness in a subgroup or subgroups, and are requesting reimbursement for those subgroups only.

Although the above situation has not occurred related to ICD therapy specifically there are several patient populations where CMS currently restricts ICD coverage based on the existing trials. These include:

- New York Heart Association (NYHC) classification IV. (Note, Medicare’s coverage of Cardiac Resynchronization Therapy defibrillators [CRT-D] in 2005 reduced the number of NYHA Class IV CHF patients who would not be covered for defibrillator implantation by CMS.)
- Had a coronary artery bypass graft (CABG) or percutaneous transluminal coronary angioplasty (PTCA) within past 3 months.
- Had an acute MI in the past 40 days.
- Patients with non-ischemic dilated cardiomyopathy (NIDCM) < 9 months.

These populations are being explored where possible in the ICD registry as well as through novel trials by the device industry and clinical researchers.

Situation 2: Applicants present CMS with results that suggest that an intervention is efficacious overall, but concern is raised that the benefits might be less in some subgroups. CMS must decide whether to reimburse the intervention without restriction, or require more information for these particularly problematic subgroups.

Throughout the ICD clinical trial history, CMS has been faced with this situation several times. Although in 5 of the 8 primary prevention trials (MADIT-I, MADIT-II, SCD-HeFT, COMPANION, and MUSTT) the ICD demonstrated a significant reduction in total mortality, two trials did not show a reduction in mortality (CABG-PATCH, DINAMIT), and the DEFINITE trial was associated with a non-significant reduction in risk of death from any cause. Based on the results of these trials however, the device industry and the clinical community have worked with CMS to define coverage for specific populations. As the trials were ongoing several areas of potential concern however were expressed by CMS or the clinical community and have been reflected in CMS’s changing coverage of ICD therapy. Examples of subgroup uncertainties within the existing trials include:

- Effectiveness by NYHA class: subgroup analysis from SCD-HeFT trial (which was positive overall) showed significant benefit from an ICD in patients with NYHA Class II but not Class III symptoms. These observations contradict other studies in which NYHA Class III patients were well represented (MADIT-I and II, DEFINTITE and COMPANION) and for that subgroup ICD was significantly efficacious.
- Effectiveness by QRS interval: Prior to the reporting of the SCD-HeFT trial, subgroup analysis from existing trials suggested less efficacy with narrower QRS interval. In 2003, CMS made a controversial coverage restriction, limiting coverage to patients with QRS > 120 ms. This restriction was lifted in 2005 after the SCD-HeFT trial results were reported.
- Effectiveness by Ejection Fraction (EF): based on an earlier meta-analysis,60 it did not appear that ICD was as effective for patients with better contraction (EF > 30 percent). Note, however, that it was questioned whether the potentially less frequent arrhythmias in this subgroup and length of followup in the trials would allow sufficient exploration of the efficacy of the ICD in this patient population.
- Effectiveness for patients whose heart failure is not caused by ischemia. The representation of patients with non-ischemic disease has been small with only the SCD-HeFT and DEFINITE trial having substantial representation
- Effectiveness by age: the mean age of patients in the clinical trials was in the early 60s, and more than 80 percent of patients were under 75 years of age. Conversely, the Medicare population is comprised of over 40 percent people over the age of 75. The efficacy of the ICD in these patients is uncertain – especially given competing mortalities.
- Effectiveness in women: only 19 percent of patients in the clinical trials were women. By contrast, the Medicare population from the ICD registry is almost 25 percent women, and the total Medicare population is over 55 percent women. The efficacy of the ICD in women is uncertain and requires further study.
- Placement of ICDs in patients who do not use them: only ~30 percent of patients in the treatment arms of ICD trials have received appropriate shocks (i.e., that could have alleviated sudden death); that nearly two-thirds of ICD recipients do not make use of the device (during the trial period) suggests a need to identify better patient-level predictors of utility – while also emphasizing the limits of our knowledge given the shortened time horizon of most clinical trials.

The effect of patient characteristics of NYHA class, age, ejection fraction, and ischemia are explored in our case study.

Situation 3: Applicants present CMS with results that suggest that an intervention is efficacious, however the trial in question has been performed on a different population (e.g., patients aged 55 to 64). The applicants wish to extend the results to patients of interest to CMS.

As detailed in Table 4 (Parts 1 and 2), although all of the ICD clinical trials have included patients over 65, the mean age of patients within the trials ranged from 57 years to 65 years with between 2 percent to 18 percent of the patient populations within a trial being over 75 years. There is uncertainty within the clinical community as to the effectiveness of the ICD in the elderly. Although the ICD may be effective in decreasing sudden death, the contribution of competing mortality, and the potential for greater morbidity need to be considered.

Situation 4: Previous completed trials have demonstrated efficacy in high-risk populations, applicants are designing a new trial in a lower-risk population of interest to CMS and request feedback concerning their proposed trial design and analysis.

The clinical trials described in this section were completed in 2003. Since that time, the exploration of the ICD in additional populations has continued. Several areas have received particular focus. These include (1) risk stratification methods for high-risk populations (e.g., use of T-wave alternans in predicting sudden cardiac death), (2) new ICD devices (e.g., trials exploring the use of remote monitoring ICDs), (3) populations which have not been well represented in trials (e.g., patients with chronic kidney disease), or (4) populations that are currently restricted from CMS coverage (e.g., early post MI patients). A listing of currently recruiting ICD trials can be found on ClinicalTrials.gov (see search results at www.clinicaltrials.gov/ct2/results?term=defibrillator&recr=Open&pg=1&flds=Xabcdefgi).