# Literature Review

## Methods

This report focuses on those situations where Bayesian these techniques might be used in CMS policymaking context. Therefore, the literature review aimed to determine whether there are circumstances under which Bayesian or frequentist statistical techniques provide design or analysis advantages for Phase III efficacy trials. Throughout the review we focused on how such approaches could modify inferences that affected policy-level decisionmaking. Although our simulation studies and case study of the ICD clinical domain also explore this question, we sought first to determine whether a review of the available published literature would provide empirical evidence.

We searched MEDLINE® using terms related to Bayesian theory and analysis, frequentist analysis, and health policy. We restricted the search to trials and review articles published in English. We also searched the reference lists of key papers and proceedings from a recent SAMSI workshop on subgroup analysis2 for potentially relevant publications. Titles and abstracts of all studies identified by these means were reviewed independently by two investigators.

The following types of articles were excluded:

- Epidemiological studies (observational or longitudinal studies).
- Genetic studies.
- Randomized controlled trials (RCT) that did not include Bayesian analysis.

Meta-analyses and cost-effectiveness analyses were included if they focused on the methods of interest and applied them in a way that allowed a comparison of Bayesian and frequentist methods. At the title-and-abstract stage, articles were included for full-text review if at least one of the two reviewers indicated that they should be included.

At the full-text review stage, articles were again reviewed by two independent reviewers and were included if they fell into one or more of the topics of interest listed above. Disagreements between reviewers were resolved through discussion.

Through all search strategies combined, we identified 334 potentially relevant citations. One hundred and ninety-seven (197) were excluded at the title-and-abstract screening stage, and another 67 were excluded at the full-text screening stage leaving a total of 70 included studies to be reviewed.

## Findings

Articles in the literature review were categorized into four themes: (1) advantages and disadvantages of Bayesian techniques in clinical trial design and analysis; (2) use of Bayesian techniques in subgroup analyses; (3) use of Bayesian techniques in meta-analysis; and (4) the effect of using Bayesian techniques on policymaking/decisionmaking.

Table 1 reports the number of included articles reviewed for each of the four themes. Note that some articles were included for more than one theme.

Table 1 Included articles by theme

Theme | Included Articles
Advantages and disadvantages of Bayesian techniques in clinical trial design and analysis (n = 41) | Austin et al., 2002^61^ Avins, 1998^22^ Berry, 1993^62^ Berry, 1998^63^ Berry, 2006^64^ Bloom et al., 2002^35^ Brophy and Joseph, 2005^9^ Brown et al., 1987^65^ Diamond and Kaul, 2004^66^ Dignam et al., 1998^18^ Dmitrienko and Wang, 2006^14^ Emerson et al., 2007^17^ Fisher, 1996^6^ Fisher, 1998^67^ Freedman and Spiegelhalter, 1989^16^ Freedman and Spiegelhalter, 1992^15^ Gennari et al., 2006^7^ George et al., 1994^19^ Goodman and Sladky, 2005^32^ Gould, 2005^68^ Greenhouse and Wasserman, 1995^69^ Grieve and Senn, 1998^70^ Howard, 2007^71^ Jones et al., 1998^30^ Kaul and Diamond, 2007^72^ Kpozehouen et al., 2005^10^ Lewis et al., 2007^13^ Lilford et al., 1995^73^ Localio et al., 2006^74^ Louis, 2005^75^ Matsuyama et al., 1998^76^ Maurer, 2005^77^ Piantadosi, 1988^78^ Pocock and Hughes, 1990^79^ Schmid et al., 2004^11^ Spiegelhalter et al., 2000^4^ Thall and Wathen, 2007^21^ Tyson et al., 2007^8^ Vail et al., 2001^80^ Wang et al., 2005^12^ Winkler, 2001^24^
Use of Bayesian techniques in subgroup analyses (n = 13) | Ades et al., 2006^38^ Brookes et al., 2001^27^ Dixon and Simon, 1991^81^ Dixon and Simon, 1992^82^ Goodman and Sladky, 2005^32^ Greenland, 2007^83^ Jones et al., 1998^30^ Moher et al., 2001^29^ Pocock et al., 2002^26^ Pocock and Hughes, 1990^79^ Rothwell, 2005^25^ Simon, 2002^31^ The European Agency for the Evaluation of Medicinal Products Committee for Proprietary Medicinal Products, 2002^28^
Use of Bayesian techniques in meta-analysis (n = 10) | Berry, 1998^63^ Bloom et al., 2002^35^ Burr et al., 2003^84^ Jones, 1995^85^ Lambert et al., 2005^86^ Nguyen et al., 2007^87^ Normand, 1999^88^ Senn, 2007^33^ Sung et al., 2006^89^ Sutton and Abrams, 2001^90^
Effect of using Bayesian techniques on policymaking/decisionmaking (n = 13) | Ades et al., 2006^38^ Berry et al., 1994^20^ Briggs, 1999^41^ Briggs, 2001^42^ Hahn and Whitehead, 2003^36^ Harrell and Shi, 2001^44^ Heitjan and Li, 2004^37^ Nixon and Thompson, 2005^39^ O’Hagan et al., 2000^43^ Sheingold, 2001^23^ Stevens and O’Hagan, 2002^45^ Vanness and Kim, 2002^40^ Winkler, 2001^24^

In what follows, we summarize our review of the literature in these four themes – while focusing these summaries on areas of interest to CMS.

### Advantages and Disadvantages of Bayesian Techniques in Clinical Trial Design and Analysis

#### Potential Advantages of Bayesian Approaches

The statistical literature contains numerous books and papers describing Bayesian theory, its associated methods as applied to medicine, and the advantages and disadvantages of Bayesian techniques in clinical trial design and analysis. The following discussion of the published literature therefore is not intended to be all-inclusive, or to provide a complete introduction to Bayesian statistical approaches. Readers are referred to Spiegelhalter and colleagues3 for a comprehensive summary on the use of Bayesian statistical approaches in the design and analysis of clinical trials, to a Health Technology Assessment by the National Institute for Health Research (NHS)4 for a complete and formal review of Bayesian methods in health technology assessment, and to the 2006 FDA guidance on the use of Bayesian methods in medical device trials.1 Many of the advantages and disadvantages of Bayesian approaches discussed here are based on review of these three sources. Note that, in addition, the International Society for Bayesian Analysis (ISBA) provides a list of Bayesian resources.5

The CMS decisionmaking context focuses mostly on situations in which clinical trials have already been performed, and in which CMS is considering whether the current evidence base is sufficient. Two areas where such decisionmaking may be helped by Bayesian approaches include the analysis of subgroups and the meta-analysis of clinical evidence as it accumulates. These topics are discussed below. Here we concentrate on three additional potential advantages of Bayesian approaches: (a) the use of prior information; (b) sample size determination; and (c) adaptive designs. It is important to note that as with frequentist statistical approaches, clinical trials based on a Bayesian approach still require scientifically sound clinical trial planning and analysis.

Bayesian statistics focus on the ability to learn from evidence as it accumulates. Prior information is combined with current information on a quantity of interest, and Bayes’ theorem is used to formally combine these two sources of information to produce an updated or posterior distribution of the quantity of interest. The use of prior information is both seen as the main strength of Bayesian techniques, while also providing the most cause for concern on the part of frequentist clinical trialists. Bayesian methods may be controversial when the prior information is based mainly on personal opinion or expert judgment, or when it is based on evidence which the decisionmaker considers subjective. In such situations, sensitivity analyses on the prior distributions are especially important. The use of prior information based on empirical evidence from existing clinical trials is less controversial, and in the CMS context this will be the most common source of prior information. Additional information could, however, be based on patient registries, pilot studies, or clinical trials of similar interventions. For a prior to be considered appropriate, the evidential basis of the prior (and any potential biases of that evidence) must be explicitly given. In addition, many emphasize the necessity of sensitivity analyses which explore a range of options for the chosen prior.4

Fisher provides a discussion of Bayesian and frequentist analysis and interpretation of clinical trials and potential controversies over the use of prior information, as well as the potential pitfalls both in their elicitation and incorporation into the existing evidence base.6 Examples of studies from the literature that explore the use of prior information and its impact on clinical trials include those by Gennari et al.,7 Tyson et al.,8 Brophy and Joseph,9 and Kpozehouen et al.10

Although the benefit of incorporating an informative prior into trial design and analysis is the most notable advantage of Bayesian statistical approaches, even when such an informative prior is not available, the Bayesian approach may still be useful through the use of interim analyses or midcourse modifications as discussed below.

The use of Bayesian approaches may modify the sample size an applicant needs to determine that the evidence is sufficient to CMS. This change could be based on either the use of prior information, as described above, or on interim “looks” during the course of a clinical trial. As discussed by Schmid and colleagues,11 the use of prior information has two potential effects on sample size estimation. If the available prior evidence provides information about the effect size, then it may reduce the required sample size. If, however, the prior evidence reflects additional uncertainty about that effect size, then the sample size may be increased. When either Bayesian or frequentist statistical techniques are used for estimating sample size, the goal is to gather enough information to make a decision about the efficacy of an intervention, while not wasting resources or putting patients at unnecessary risk. Bayesian approaches allow their users not to specify a particular sample size, but rather a particular criterion at which to stop the trial. At any point during the trial period, Bayesian techniques can be used to obtain the posterior distribution for the sample size, to compute the expected additional number of observations needed to meet the pre-specified stopping criterion, and to potentially stop the trial at the precise point where enough information has been gathered to answer the clinical or policy question of interest. An example of the use of Bayesian approaches in sample size determination is provided by Wang and colleagues.12

Finally, the use of Bayesian approaches may allow adaptive designs to be incorporated into clinical trials. Such trial designs may allow an unfavorable treatment arm to be dropped midcourse during the trial, or permit modifications to the randomization scheme to occur. Although the frequentist approach includes sequential analysis techniques that do not require pre-specified sample sizes, it is generally agreed that the Bayesian approach is particularly well suited to the topic of interim review.

The decision to stop a randomized clinical trial based on an interim analysis is best made by weighing the value (both costs and benefits) of the additional information that would be gained if further subjects were enrolled in the trial. Lewis and colleagues13 provide a discussion of how such a comparison is difficult using frequentist statistical approaches and give an example application of Bayesian approaches. Bayesian approaches to monitoring clinical trials (and potentially stopping a trial early for futility or efficacy) depend on the underlying theory that a trial’s outcome can be considered positive or negative if it is demonstrated that the posterior probability of a clinically important improvement is greater than a pre-specified threshold. This criterion, however, is dependent both on interim and future data. Because the future data are not available at the time of the interim analysis, they are replaced by the values predicted based on the interim data and the prior distribution of the treatment effect. Dmitrienko and Wang14 and Freedman and Spiegelhalter15,16 reviewed Bayesian strategies for monitoring clinical trial data and compare the Bayesian approach to more frequentist approaches. Dmitrienko and Wang14 focus on the sensitivity of stopping rules to the choice of prior distribution and provide guidelines for choosing a prior distribution of the treatment effect. In their analysis, they emphasize that the choice of prior distributions depends on the trial’s objective, development phase and patient population. Their findings demonstrate that weak priors are more likely to trigger an early stopping in futility monitoring compared to strong priors. This sensitivity to negative treatment differences may be justified in large mortality trials because it helps reduce the exposure of critically ill patients to ineffective drugs. However, using such weak priors in most proof-of-concept studies may result in unacceptably high early termination rates. In these situations, stronger aggressive (i.e. informative) priors are preferable.14 Emerson and colleagues17 also expand on the importance of including different prior distributions when considering Bayesian stopping rules. Dignam and colleagues18 provide a discussion of a controversial trial stoppage based on interim results and demonstrate how the use of a Bayesian approach allows exploration of a range of prior beliefs regarding the efficacy of treatment and the appropriateness of the early termination of the trial. George and colleagues19 and Berry and colleagues20 provide additional examples of the use of Bayesian statistical approaches in stopping a clinical trial early, and describe how this approach differs from frequentist techniques.

In addition to early stopping of trials, Bayesian approaches are used for adaptive randomization within clinical trials. Such adaptive randomizations may allow providers to enroll patients into a clinical trial, but with treatment assigned based on the performance to date, thereby allowing randomization to be based on accumulating data during a trial. Alternatively, the probability of assigning the next patient to a particular treatment group can be changed because of baseline prognostic factors. Thall and Wathen21 discuss some of the limitations of adaptive randomization and methods of addressing these potential problems. Avins22 provides an interesting discussion of the ethics of subject allocation within randomized controlled trials and how Bayesian approaches may be useful.

#### Potential Disadvantages of Bayesian Approaches

Although much of our review of the literature focuses on the potential advantages of Bayesian statistical approaches in clinical trial design and analysis – there are as expected also potential difficulties that accompany their use.1 These difficulties include:

- The identification and pre-specification of prior information.
- The development and pre-specification of the underlying mathematical model.
- The need for statistical and computational expertise.
- The difficulties involved in conveying the results of a Bayesian trial given any unfamiliarity with the methods among policymakers or stakeholders.
- Facilitating interpretation and consensus-building when analysis of trial results by frequentist and Bayesian approaches differ.

Many of these difficulties as they specifically apply to healthcare decisions and policymaking are discussed by Sheingold23 and Winkler.24 Both discussions also focus on ways of making Bayesian approaches transparent and useful to policymakers and provide a useful resource for CMS and policymakers.

In the next two sections we discuss two areas where the use of Bayesian approaches may have substantial benefits compared with frequentist approaches specifically in the CMS decisionmaking context: (1) the analysis of specific subgroups, either within a given trial or between trials as the evidence accumulates; and (2) the meta-analysis of a group of clinical trials exploring an intervention of interest.

### Use of Bayesian Techniques in Subgroup Analyses

#### CMS Context

We assume that CMS will potentially encounter all four situations described above and require interpretation of subgroup analysis. For simplicity of presentation, and in order to isolate those issues that are unique to subgroups, we assume that a single trial is at issue; in particular, that either data from a single trial are being analyzed or that CMS and industry representatives are consulting about the design of an upcoming trial. Meta-analysis is considered below.

#### Medical Context

Frequentist randomized trials are designed to identify average effects of interventions, the philosophy being to estimate the efficacy of the intervention for “typical” patients. However, patients are biologically heterogeneous, and it is consistent with medical science to believe that not only will individual patients differ in their response to an intervention, but that groups of patients will do so as well. This level of biological heterogeneity is becoming increasingly apparent through, among other things, the genomics revolution. Accordingly, the desire to explore whether and how the efficacy of an intervention differs across subgroups is a medically and scientifically reasonable thing to do. The problem is not with this intention, but rather trials that are usually not designed to facilitate definitive subgroup analyses, and even in the best case, subgroup analyses induce various issues of statistical methodology that makes their interpretation difficult.

#### Statistical Context

With rather modest exceptions, Bayesian and frequentist statisticians agree on the nature of the methodological problems associated with subgroup analysis. Their disagreement lies in how best to address these problems. The basics of the Bayesian and frequentist approaches have been described elsewhere, and this section assumes that the reader is familiar with both.

##### Frequentist position

The frequentist perspective is well summarized by Rothwell,25 who cites many of the other frequentist articles described below – especially those of Pocock et al.26 and Brookes et al.27 – and is particularly recommended as a sound listing of action items implied by the frequentist philosophy. This summary will primarily rely on Rothwell.25 Current perspectives such as those described by The European Agency for the Evaluation of Medicinal Products Committee for Proprietary Medicinal Products28 or by Moher and colleagues,29 are based on the frequentist perspective. Rothwell25 states that the situations in which subgroup analyses should be considered include those in which there is potential heterogeneity of treatment effect related to risk or to pathophysiology, where there are clinically important questions related to the practical application of treatment, or where underuse of the treatment in routine clinical practice is due to uncertainty about the benefit. However, he provides recommendations for trial design, analysis, and interpretation of such subgroup analyses.

The problems that the frequentists are trying to address in their recommendations include the following. First (defining statistical significance as p < 0.05), comparison of statistical significance across subgroups can lead to flawed conclusions. Suppose that in subgroup A, the confidence interval for the treatment effect is 0.2 to 3.8, p = 0.04, whereas in subgroup B the confidence interval for the treatment effect is −0.5 to 2.5, p = 0.08. The confidence intervals overlap, and in all probability a formal test for interaction would be non-significant, but the intervention effect in subgroup A is statistically significant, whereas the intervention effect in subgroup B is not. However, there is little or no real difference across subgroups.

Second, the more subgroup analyses there are, the greater the likelihood of spurious results. Often, the emphasis is on falsely positive findings, in which case this phenomenon is termed the multiple-inference, multiplicity, or multiple-testing problem. It is also possible for the spurious results to be falsely negative. An example is when the intervention effect is actually the same in all groups but by chance appears to be of a smaller magnitude in some subgroups than others.

Third, when subgroup analyses are made in isolation they can potentially suffer from having small sample sizes, which in turn can lead to instability in conclusions and often to low statistical power as well. If the randomization is not stratified by the subgroup in question, it is possible that the subgroups in question will be unbalanced (e.g., one intervention having more patients with a good prognosis than the other), which must be accounted for in order to draw appropriate conclusions.

The frequentist response to these issues is two-fold, pertaining to design and analysis. Regarding design, post hoc analyses of subgroups are de-emphasized and in extreme cases forbidden. Put in more positive terms, the frequentist approach emphasizes the specification, on clinical grounds, of potentially important subgroups, and places greater weight on those (presumably clinically well grounded) subgroup analyses that are pre-specified. This approach does not necessarily solve the problem of multiple subgroup analyses, since large numbers of such analyses could potentially be specified, but in practice often serves to limit the number of subgroup analyses to a manageable level.

The main analytic response to the above difficulties is to adopt the strategy of only considering subgroup analyses if an initial test for intervention-by-subgroup interaction is statistically significant. The intention of this strategy is to reduce the number of spurious findings of unusual effects in individual subgroups. For the same reason, it is sometimes the case that the set of potential interactions includes only those interactions that are specified a priori, but other analysts will test for unexpected interactions and use a more stringent threshold for such tests. If the test for interaction is positive, analyses of subgroups might make adjustments for multiplicity. A simple such adjustment is the Bonferronicorrection. For example, if two subgroup analyses are being considered, then α= 0.025 (i.e., 0.05/2, the number of statistical tests) is used as a revised threshold for statistical significance, and confidence intervals are similarly inflated by a Bonferroni correction factor.

##### Bayesian critique

The Bayesian critique of the frequentist position is both technical and philosophical. The technical portion of the critique is that the test for interaction that forms the underpinning of the frequentist approach does not necessarily have good properties. In the first place, this test for interaction often has low power, which frequentists believe to be an advantage because of its conservatism but which Bayesians believe to be a disadvantage because of its tendency to miss real differences in efficacy across subgroups.

A second problem lies not with the test for interaction per se, but instead lies with the analysis strategy within which that test for interaction is imbedded.30 In particular, the problem lies in making a “go/no go” decision based on whether the p-value for this test for interaction falls below 0.05.

One component of the philosophical portion of the Bayesian critique pertains to the way that frequentists frame the multiplicity problem. Bayesian statisticians believe that it is intellectually inconsistent for one analyst that has performed 99 previous subgroup analyses and then discovered an interesting result in subgroup analysis number 100 to come to a different conclusion than another analyst that begins with the latter subgroup analysis, the rationale being that the data are the same for both analysts as is the true state of nature. Bayesian statisticians believe that they have solved the multiplicity problem through reframing it, as discussed below.

A second component of this philosophical critique pertains to the assumption of no differential efficacy among subgroups that is represented by the null hypothesis in the frequentist test for interaction. To a Bayesian, such an assumption is inconsistent with the notion of biological heterogeneity (i.e., discussed under the medical context). Rather than having to make an artificial distinction, based on a single statistical test, whether such heterogeneity is present or absent, the Bayesian prefers to (a) follow the biological insight that heterogeneity is almost always present; (b) include parameters representing this heterogeneity in their models; and (c) include the quantitative exploration of this heterogeneity as part of their analysis strategy.

A final component of this philosophical critique pertains to the problem of small sample sizes. In the most extreme version of the frequentist position, the only information that can be considered about a subgroup pertains to the subgroup itself, which can lead to small sample sizes within that subgroup. Bayesians, on the other hand, use information (i.e., “borrow strength”) from similar subgroups to enhance the amount of evidence available for any particular subgroup.

##### Bayesian position

The Bayesian position is perhaps most clearly elucidated by Simon31 and illustrated by Goodman and Sladky.32 Its basics are also covered in various tutorial articles, not discussed here.

Some statistical price must be paid in order to address the problems of multiplicity and the instability of estimates within small subgroups. The price that Bayesians are willing to pay is through (a) specifying a model delineating the nature of the anticipated interactions; and then (b) specifying, through a prior distribution, estimates associated with the parameters of this model (i.e., specifying the anticipated interaction terms). Once the data are collected, the estimates within any subgroup are not based on that subgroup alone (as is the case in the frequentist approach), but instead are a weighted average of the subgroup in question and all other subgroups. Technically, and as described in detail elsewhere, the methodology can be summarized by the expression prior distribution plus data equals posterior distribution. Thus, at the conclusion of a Bayesian analysis, the estimated efficacy within any subgroup will be a distribution whose central (or modal) value reflects the most plausible point estimate and whose spread provides information about the range of reasonable values.

The effect of this procedure is to “shrink” the estimates of “extreme” subgroups – that is, subgroups that have extreme estimates of efficacy, and also subgroups that have extremely small sample sizes – toward the main effect of efficacy in the population as a whole. Very skeptical prior distributions give greater weight to the notion that interactions are unlikely, and thus require dramatic differences between subgroups in order to conclude that substantial differences exist.

Those that advocate for a comprehensive Bayesian approach argue that neither of the above elements of the statistical price is particularly problematic. Regarding the first point, Bayesians argue that the principle of biological heterogeneity suggests that it is scientifically sound to assume that subgroup effects exist, and thus that modeling these effects is a positive rather than a negative, and also contributes toward greater transparency in decisionmaking. Regarding the second point, Bayesians regard the specification of a prior distribution as being consistent with the way that decisionmakers frame many actual decision problems (i.e., as preliminary beliefs altered by data into revised beliefs), and regard the specification of those prior beliefs as providing important elements of transparency. Sensitivity analyses can be performed in order to assess how the conclusions are altered by postulating different prior distributions. Finally, skeptical prior distributions can be specified, thus providing a high hurdle before declaring subgroup effects to be different – in essence, the same idea of a high hurdle that underpins the frequentist test for interaction, but implemented in a fashion that Bayesians believe to be preferable.

#### Comments

Fortunately, the entire debate of whether the Bayesian worldview is uniformly preferable to that of the frequentist can be avoided by taking the position of Simon;31 namely, that Bayesian methods work very well in some situations and not so well in others, and that the subgroup analysis problem is one that is unusually well matched to the Bayesian approach. Both Bayesians and frequentists acknowledge the same set of problems associated with subgroup analyses – namely, the potential inconsistency in conclusions obtained from analyzing multiple subgroups. These problems are exacerbated when subgroups are small and the analyses are made in the absence of an explicit theoretical model. This potential inconsistency is illustrated in our CMS Situation 1 (requesting determination that the evidence demonstrating efficacy is sufficient for select subgroups) and Situation 2 (potential of limited efficacy in select subgroups) – that is, the data suggest that efficacy associated with one or more subgroups might differ from the others leaving CMS with the problem of whether to believe that the effectiveness of the intervention actually differs.

The clinical trial literature and many policymaking groups acknowledge the problems associated with subgroup analyses and implicitly or explicitly adopt the frequentist position in response. One element of this response with which Bayesians would agree is the importance of transparently specifying the analyst’s conceptual model ahead of time. Here, the main difference between Bayesians and frequentists is precisely how that model is specified. Another point of agreement is that the test for interaction proposed by frequentists is conservative (i.e. avoids falsely declaring statistical significant), in the sense that it is more likely to miss true subgroup effects than it is to falsely declare that subgroup effects exist.

The primary point of dispute is how to respond to this conservatism. Frequentists interpret this conservatism as an advantage. Bayesians prefer a strategy that has a better chance of discovering subgroup effects when they in fact exist. The Bayesian approach even provides a way forward in CMS Situation #3 (extending current results to subgroups not well represented in the trials) for which there is no equivalent frequentist method – namely, to (a) verify that the biological science is not markedly different for Medicare beneficiaries or to make a conceptually based estimate of the degree of difference; and (b) use this assumption, plus data from other subgroups, to posit a distribution of possible efficacy values in the currently unstudied subgroup. The paper by Goodman and Sladky32 provides a particularly thoughtful example of how prior distributions can be specified.

As illustrated by Simon31 and Goodman and Sladky,32 policymakers that are considering Bayesian methods should insist on prior distributions that are (a) scientifically justified, such as by a conceptual model or a meta-analysis; and (b) skeptical. One implication of a skeptical prior distribution is that results from extreme subgroups – in particular, from subgroups based on extremely small sample sizes – will shrink toward the population mean. In particular, in Situation 1 and Situation 2, when the subgroup in question is small neither frequentist nor Bayesian methods are likely to conclude that the results in the anomalous subgroup are real.

Another advantage of a skeptical prior distribution is that it would serve to standardize the application of Bayesian methods in practice. Advocates of the Bayesian position often seem to underestimate the importance of this standardization within a regulatory context, where analysts are not always disinterested observers but instead may be adopting a position of advocacy. Indeed, this standardization is in many cases a significant advantage of frequentist methods which, although not necessarily optimal in all cases, provide a set of ground rules that can be agreed upon ahead of time and, thus, are in that sense ‘objective’.

The best solution to all of the above issues is replication and validation. In designing subsequent studies, Bayesian methods offer the potential for smaller and more focused studies.32 This issue is discussed in detail elsewhere. In addition, note that when making coverage decisions CMS is in general interested in more inclusive trials that have a large enough sample size to detect a health benefit, not just for the group with the highest likelihood of showing efficacy.

### Use of Bayesian Techniques for Meta-Analysis of Existing Trials

As the number of clinical trials assessing a given intervention increases, often with differing findings, policymakers are tasked with how best to evaluate the collection of existing trials, and whether the use of Bayesian techniques is helpful in such analysis. The literature considers two separate cases of meta-analyses: (a) all the evidence consists of similar trials with similar design, similar patient populations, similar interventions, and similar outcome measures; and (b) other evidence is available such as that from dissimilar trials, which may differ in terms of interventions or patient groups, from non-trial sources such as from observational studies or registries, or from expert judgment.

#### Case 1 Similar Trials

Three models are typically used: (a) a fixed-effect model; (b) a random-effects model with all parameters estimated from the trials in question; and (c) a random-effects model using outside information. Frequentists utilize either models A or B above. Bayesians utilize either models B or C above. Model B is termed the “empirical Bayesian” solution, whereas model C is termed the “fully Bayesian” solution.

Symbolically, denote the efficacy measure in study “k” by λ_k_. The fixed-effect model assumes that these λ_k_ are the same for all studies, and can thus be denoted by λ. Each study will generate an observed λ_k_ and a within-study standard error σ_k_. Typically, σ_k_ will decrease with sample size; as sample size increases, the standard error of the estimated intervention effect λ_k_ tends to decrease. The fixed-effect model uses as its estimate of λ a weighted average of the λ_k_, with weighting factor 1/V_k_, where V_k_ denotes variance. Thus, more precise studies will receive greater weight in the estimation of λ.

The fixed-effect model violates the principle of biological heterogeneity (discussed in the subgroup analysis section); that is, it is more plausible to postulate that there is some degree of heterogeneity in the effects being measured than to believe that they are absolutely identical. Nevertheless, in practice this assumption is not intended to be literally true but only approximately so and, thus, some analysts (e.g., Senn33) recommend beginning with a fixed-effect analysis as a standard of comparison.

The random-effects model relaxes the assumption that the efficacy being measured is identical from study to study. Each individual study still generates an efficacy estimate λ_k_ and precision σ_k_ (or, equivalently, V_k_). In order to implement the notion that efficacy can differ across trials, it is assumed that each λ_k_ is drawn from a “super-population distribution” having mean λ_0_ and standard deviation τ. The estimate of λ_0_ is still a weighted average of the λ_k_, with the weighting factor now being v_k_ + τ^2^, where (to recapitulate) τ^2^ is the between-study variance.

The main implications of this procedure are: (a) less precise studies are given more weight when compared with the fixed-effect model; (b) in effect, estimates from extreme studies are shrunk toward the overall mean; and (c) estimates of λ_0_ from the random-effects model are less precise than estimates of λ from the fixed-effect model. Just as the absolute consistency of the effects is a useful fiction within the fixed-effect model, the existence of a super-population distribution is a useful fiction in the random-effects model. This fiction is made more actionable by the notion of “exchangeability,” which in essence states that the analyst has no reason to anticipate that the efficacy estimate from any particular study will be either higher or lower than average.

In practice, the rate-limiting factor in the estimation of τ is the number of studies, not the sample size within study. Accordingly, estimates of τ from meta-analyses of small to moderate numbers of studies can be clinically implausible, and deleteriously affect the statistical properties of the analysis. Note that what is considered as a small to moderate number of studies depends on the variability of the outcome of interest within and between trials and goals of analysis. However, this empirical Bayesian approach does have the advantage (or disadvantage, depending on one’s perspective) of being entirely data-based.

In the fully Bayesian solution, σ_k_ and τ are considered to be random variables, and require external prior estimates. The results are often sensitive to these assumptions about the prior distribution. Accordingly, the advantages of the fully Bayesian solution are more prominent in Case 2 described below.

#### Case 2 Dissimilar Information

The fully Bayesian solution is the only approach that accommodates disparate types of information. Examples of such information are randomized trial data from similar interventions or similar patient subgroups, non-randomized trial data in circumstances where few randomized trials are available, and expert judgment. The impact of this external information can be adjusted through the precision of the prior distributions which summarize that information. For example, suppose that information from a small randomized trial is to be supplemented by external information from observational sources such as registries, expert opinion, and the like. The precision associated with the efficacy estimate from the randomized trial is known. If the analyst wishes to assign equal importance to the two types of information, the prior distribution can be assumed to have similar precision. If the analyst wishes to assign greater importance to the prior information, this prior distribution can be assumed to have greater precision, and similarly, if the analyst wishes to assign less importance to the prior information, this prior distribution can be assumed to have less precision. This basic idea can be implemented in various ways and is discussed in more detail in two publications by Spiegelhalter et al.4,34 All of the previously described advantages and disadvantages of using external and expert-derived data apply.

#### Comment

Direct comparisons of meta-analyses between frequentist and Bayesian approaches (e.g., Bloom et al.35) do not always yield consistent results – in particular, sometimes the results of the two approaches are similar and sometimes they are different. However, some observations do appear to be reasonably consistent.

- Estimates of efficacy from random-effect models have less precision than estimates of efficacy from fixed-effect models.
- Fixed-effect models give greater weight to larger studies than do random-effects models.
- Both approaches struggle a bit when the number of studies is small to moderate. In the fixed-effect model, this is reflected by a test for heterogeneity that has low power. In the random-effects models, this is reflected by the tendency for the results to be sensitive to the estimate (model B) or assumptions (model C) about τ.
- The results of the fully Bayesian analysis are most likely to differ from others when relatively little information is available from the data. This is, in general, the most dangerous circumstance for drawing definitive conclusions – which phenomenon should be illustrated by a careful sensitivity analysis.
- A particularly natural situation for the application of Bayesian statistics occurs when (a) the amount of randomized trial data is modest (e.g., as would be the case for a small subgroup of patients aged 65 and above); and (b) external information is available (e.g., from other trials with designs that are similar but not identical, registries, or expert opinion), but this external information is of such disparate form that it cannot easily be brought to bear using the frequentist paradigm.

### Effect of Using Bayesian Techniques on Policymaking and Decisionmaking

The literature regarding he policy implications of the application of frequentist or Bayesian methods generally falls into two major categories: (a) the technical issues that influence applicability of each approach for health economic evaluations, in particular cost-effectiveness and net-benefit, and (b) the sources and possible solutions to policymaker resistance to the use of Bayesian methods.

#### Applicability of Frequentist vs. Bayesian Approaches for Health Economic Evaluations

The majority of articles in the current literature fall into this category. In addition to the critique of the relative theoretical merits of one approach compared to the other, the key messages are: (a) health economic calculations such as incremental cost-effectiveness ratios, cost-effectiveness acceptability curves, and net-benefit calculations can be performed within a Bayesian framework, and (b) as with other metrics emerging from research studies, if a non informative prior is used the results of frequentist and Bayesian analyses are comparable.

Several papers illustrate the application of Bayesian methods to cost-related analyses. Hahn and Whitehead36 applied data from a comparative study of laparoscopic vs. open surgery for repair of inguinal hernia, specifically calculating and plotting net benefit as a function of willingness to pay for units of health effectiveness. With the exception of the interpretation, using a non-informative prior led to comparable results with both approaches. They advocate for the Bayesian approach because of its natural interpretation in a decisionmaking context but warn that misspecification of a prior distribution can lead to less than robust conclusions. Similarly, Heitjan and Li37 apply data from a cardiovascular trial to calculate incremental net health benefit using Bayesian methods, advocating for the value in producing more interpretable, flexible results. However, like Hahn and Whitehead,36 they do not offer direct evidence of the attractiveness of the outputs to decisionmakers.

Ades et al.38 provide a conceptual case for the use of Bayesian evidence synthesis in the context of cost-effectiveness decision models; decision models are noted to be increasingly well accepted policy analysis tools in health care. While written to provide guidance on the use of the techniques, they point out that “[f]urther research is needed on how to model particular evidence structures, how to use historical evidence and expert opinion to inform priors, and how to understand the…information around complex networks of evidence.”

Nixon and Thompson39 focus on the potential utility of Bayesian methods for addressing the importance of subgroup differences; it is suggested that these methods hold promise in the context of cost-effectiveness studies, noting many of the issues raised by Bayesian versus frequentist approaches to subgroups identified in the relative efficacy literature (see the section on “Use of Bayesian Techniques in Subgroup Analyses,” above).

In the same vein, Vanness and Kim40 apply Bayesian methods to data from a study of ganciclovir prophylaxis in liver transplantation. In addition to demonstrating the application of the methodology, they also suggest that Bayesian methods should be more attractive to decisionmakers as the outputs have natural interpretations (and can be directly incorporated into analyses which explicitly incorporate realistic representations of the losses associated with decisionmaking errors). The study does not provide any empirical support for that suggestion.

Three additional studies41–43 further illustrate the application of Bayesian methods to the calculation of cost-relevant metrics. However, they do not provide further evidence regarding how the Bayesian approach leads to more useful analyses to decisionmakers than do frequentist methods.

#### Sources and Possible Solutions to Policymaker Resistance to the Use of Bayesian Methods

Two thought articles23,24 focused on the question of why policymakers (and others) have been resistant to the application of Bayesian methods and how such resistance might be overcome. After laying out the case for preferring a Bayesian framework for evaluation of healthcare interventions, Winkler24 notes several possible explanations for why such an advantageous approach is not used more widely. He considers and dismisses as crucial the philosophical issues (i.e., the notion of subjective versus objective probability), as not particularly relevant to decisionmakers and, indeed, notes that decisionmakers are most apt to function in a Bayesian mode while appearing to embrace the frequentist analytic approach. Note that the relevance of information provided by Bayesian approaches to decisionmakers and ease of interpretation of these findings are highlighted by Harrell and Shih in their related analysis.44 In his research, Winkler lists five core problems with acceptance of the Bayesian approach: (a) there is inadequate training in Bayesian statistics; (b) software to implement Bayesian techniques are less accessible; (c) application of Bayesian techniques requires thinking while frequentist approaches can be implemented relatively thoughtlessly; (d) there are few role models for successful application of Bayesian techniques; (e) there is a strong frequentist tradition that will be difficult to overcome – it is accepted as the standard by journals, policy makers, regulators, and courts. On the latter point, he considers the possibility that one core issue is the belief by recipients of analyses that frequentist approaches are inherently more “objective” and thus less subject to manipulation. In response to this list, he suggests the following:

1. More materials for Bayesian training.
2. Easier-to-use software.
3. Better procedures for choosing prior distributions.
4. Standards for presentation of results.
5. Creating illustrative cases of the application of Bayesian techniques to decisionmaking problems in health care.
6. Demonstrating the advantages of Bayesian techniques in important healthcare decisions, including consideration of utilities/loss functions.
7. “Selling” the case for Bayesian methods more effectively (i.e., have people demand a Bayesian analysis).

Sheingold23 takes a similar approach, but from the perspective of a decisionmaker looking to appreciate the value of Bayesian methods. He observes that most decisionmakers are implicitly Bayesian; they are just not drawn to the formal methods (“new and different results are carefully scrutinized, although usually not with formal Bayesian methods, when they seem to contradict our prior knowledge”). In addition to the explanations described by Winkler, he highlights the key importance of added value, noting that approaches that require movement from a relatively stable and comfortable position requires demonstration of a significant anomaly – “an outcome that could not be predicted by the current paradigm.” In terms of the Medicare decisionmaking process, he points out 3 areas of resistance: (a) the methods are difficult to explain to stakeholders; (b) the decisionmaking process cannot be fully encompassed by any analytic process and indeed such a process may contradict goals of key stakeholders; and (c) there is no clear demonstrated anomaly related to frequentist methods. His prescription for overcoming these barriers is similar to that of Winkler, with stress on what Bayesian methods add to the existing decisionmaking processes.

Recognizing that a potential weakness of the application of Bayesian methods in the policy domain is the worrisome role of the prior distribution, Stevens and O’Hagan45 focus on the notion of developing a “genuine prior.” The genuine prior is an informative prior that “would represent all available evidence that has been formally synthesized into probability distributions.” In the context of decisionmaking, they acknowledge that there is no well accepted process for elicitation of prior information and so any genuine prior should be judged relative to a non-informative prior for purposes of assessing the extent to which the informative prior influenced the analysis (and presumably to judge how intensely a decisionmaker must scrutinize how the “genuine prior” was constructed). In conclusion, they recommend that “[g]uidelines should be developed that provide recommendations for the elicitation process and the synthesis of such information into probability distributions. Submissions of evidence on the cost-effectiveness of new interventions using the Bayesian approach must include supporting documentation that demonstrates clearly that a formal process of elicitation has been followed if the prior information is to be accepted as credible.”