# Framing the Problem: CMS Contexts (or “Situations”)

We defined four decisional contexts or situations where CMS may consider the use of Bayesian approaches, and throughout our analysis we continually refer back to how our findings may apply to these contexts. The four contexts are:

- Situation 1: Applicants present CMS with results that suggest no or minimal efficacy of an intervention for the overall population, but apparent effectiveness in a subgroup or subgroups of patients, and are requesting reimbursement for those subgroups only.
- Situation 2: Applicants present CMS with results that suggest that an intervention is effective overall, but concern is raised that the benefits might be [underlined: less] effective in some subgroups.
- Situation 3: Applicants present CMS with results that suggest that an intervention is effective, but the trial in question has been performed on a different population (e.g. patients aged 55 to 64). The applicants wish to extend the results to patients of interest to CMS.
- Situation 4: Previous completed trials have demonstrated effectiveness in high-risk populations, and applicants are designing a new trial in a lower-risk population of interest to CMS and request feedback concerning their proposed trial design and analysis.

For the purposes of this work, we assume that CMS’s evaluation task in each of the above situations involves three key steps:

1. Translating CMS’ general criterion of whether a given intervention is deemed “reasonable and necessary” into specific criteria describing the outcomes that are necessary and sufficient to characterize the intervention’s value to the target population.
2. Assessing the degree to which the intervention in question promotes improvements in those outcomes to the target populations.
3. Judging whether those improvements are sufficient to implement into policy.

These evaluation tasks can be performed using two approaches: frequentist statistical techniques or Bayesian techniques. Step 1 of establishing the specific criteria by which an intervention is assessed is basic to both evaluation approaches. Step 2 involves analysis of evidence, typically using frequentist statistical tools for assigning levels of statistical significance, and Step 3 involves a mix of quantitative and qualitative approaches. Quantitative approaches might include simple criteria such as “are there X trials each with a p value < y?,” or more involved approaches based on meta-analysis. Qualitative approaches aim to promote decisionmaking by assessing the “sense of the committee” and can be informal or formal such as the modified Delphi method.

What is distinctive about the two approaches is the way they address the latter two steps. In a frequentist evaluation approach, these steps are treated as separate. The Bayesian approach treats the latter two steps as integrated and may be characterized as assessing the adequacy of evidence for the purpose of decisionmaking or action. In particular, a Bayesian analysis of any body of evidence focuses on estimating the “strength of belief” regarding any particular measure, for example, “Study X leads me to be Y percent confident that the effect of the intervention is greater than Z”. Furthermore, the Bayesian approach leads to natural interpretations of multiple studies, each contributing to a body of evidence, and also provides a conceptually consistent framework for linking various forms of evidence to construct aggregate inferences.

Whatever the theoretical or philosophical benefits of any particular evaluation approach, what is ultimately of interest to CMS and society is how to achieve the practical goals of promoting improved health outcomes for Medicare beneficiaries. It is important to note that the evaluation task is not pursued in a vacuum, as multiple stakeholders are involved with a wide variety of interests. Evaluation and ultimate decisionmaking occurs through a process which has social, political, and economic ramifications. It is crucial that any evaluation strategy is in harmony with the current decisionmaking context and process. In addition to achieving the analytical goal of extracting a correct inference from a body of evidence, an evaluation strategy should promote the broader goals of transparency, clarity, efficiency, and accommodation of multiple objectives.