# Introduction, Tutorial, and Overview of Project

## Introduction

The phrase “Bayesian statistics”^a^ refers to an approach and method of analysis which combines prior knowledge and accumulated experience with current information in order to make inferences about a quantity of interest. Using Bayes’ theorem, Bayesian approaches are able to provide a formal method of learning from evidence as it accumulates. In the past, Bayesian approaches to clinical trial design and analysis have been difficult, given their computational intensity and their sometimes controversial method of using prior information. As a result of recent breakthroughs in computational algorithms, the computational limitations of Bayesian approaches have mostly been mitigated. The potential benefits of Bayesian approaches – especially when good prior information is available – have allowed the use of these techniques to become more popular within the clinical trial community.

a A glossary of terms is provided at the end of this report. Terms defined in the glossary appear in bold and italicized where they first appear in the main text of the report.

As evidence of the rise of Bayesian statistical approaches in the clinical trial and regulatory communities, in 2006 the U.S. Food and Drug Administration (FDA) Center for Devices and Radiological Health (CDRH) issued draft guidance for industry and FDA staff entitled “Guidance for the Use of Bayesian Statistics in Medical Device Clinical Trials.”1 Although this guidance from the FDA provides a useful overview of Bayesian statistics and the recommended methods for employing such approaches in clinical trial design and analysis, it focuses on the use of Bayesian techniques at the FDA approval stage rather than at the stage at which the Centers for Medicare & Medicaid Services (CMS) determines whether evidence is sufficient to support their needed coverage decisions. In addition, it has been suggested that the FDA CDRH guidance in its current form puts substantial emphasis on calibrating Bayesian findings to classical (frequentist) calculations and therefore does not take full advantage of the Bayesian approach.

As Bayesian statistical techniques have gained broader acceptance within the clinical trial community, CMS seeks to assess the potential impact of such techniques on their policy-level decisionmaking. The Coverage and Analysis Group at the CMS requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center (EPC): Duke EPC (Contract Number: HHSA 290 2007 10066 I).

The overall goal of this project is to provide CMS with a general approach for assessing the use of Bayesian techniques in its evidence-based policy processes. To reach this goal we had three specific aims:

1. To provide a synthesis of existing research regarding the advantages and disadvantages of Bayesian techniques in clinical trial design and analysis, focusing on how such techniques can modify inferences that affect policy-level decisionmaking.
2. To explore Bayesian techniques in the CMS context through the specific clinical domain of the prevention of sudden cardiac death (SCD) trials to determine the effective use of the implantable cardioverter defibrillator (ICD).
3. To use the findings from the above two investigations to determine lessons learned specific to the CMS context, and to provide CMS with findings on: (a) the inclusion of studies that apply Bayesian techniques; (b) the circumstances in which such techniques may or may not be particularly appropriate; and (c) how such techniques can be used in conjunction with other data sources available to CMS, such as registries.

To help orient the reader we first provide an overview of the structure of the report, and then provide a basic tutorial on Bayesian statistical approaches and their use in clinical trial design and analysis.

## Overview of the Report

There are numerous areas within clinical trial design and analysis where the use of Bayesian analyses can be and has been explored. These include applications to planning a clinical trial, performing and analyzing the trial, planning subsequent trials, combining data from multiple trials (and other sources), and incorporating registry data into the evidence base. These different potential applications of Bayesian approaches and the relative advantages and disadvantages of Bayesian approaches compared with more classical techniques are summarized in the literature review in Chapter 3.

Our main focus in this report, however, is on one of the potential applications of Bayesian analysis – subgroup analysis – within individual trials and across multiple trials. We chose this focus because it is a natural application of Bayesian methods from the CMS perspective, since (a) CMS is often presented with subgroup analyses that might suggest that a drug or device might work better or worse for particular categories of patient; (b) CMS is usually more interested in patients aged 65 years and above; and (c) results for particular subgroups are often based on small sample sizes, and/or are otherwise inconsistent, and thus require the introduction of additional information in order to draw sound conclusions. In Chapter 2 we define four decisional contexts or situations where CMS may consider the use of Bayesian approaches, and throughout our analysis we continually refer back to how our findings may apply to these contexts.

After defining these contexts, we provide a review of the literature, describing current knowledge of subgroup analyses from both the Bayesian and frequentist perspectives. We sought to determine whether there are circumstances under which Bayesian or frequentist statistical techniques provide design or analysis advantages for Phase III efficacy trials. In particular, we summarize the published literature exploring how Bayesian techniques of clinical trial design and analysis could modify inferences and potentially affect CMS policy-level decisionmaking.

We then illustrate the application of these findings to a clinical domain of interest to CMS – specifically, clinical trials evaluating the use of implantable cardioverter defibrillator (ICD) therapy in the prevention of sudden cardiac death (SCD). We used both simulation studies and a case study evaluating patient-level data from eight ICD clinical trials to highlight the advantages and disadvantages of Bayesian techniques as compared to frequentist approaches. These simulations are intended to illustrate and supplement the literature review.

We use the data from the ICD trials to illustrate how the analyses of these data might proceed using the Bayesian and frequentist perspectives. The primary goal of this case study is to help the reader visualize how a Bayesian analysis would proceed and be reported. In order to illustrate the two types of data that an analyst might encounter in practice, the case study includes both analyses of raw data and of summary data. We also explore the use of Bayesian statistical techniques in a clinical domain where registry data are available – such as those clinical domains where CMS issues a national coverage decision requiring, as a condition of coverage, the collection of additional patient data to supplement standard claims data (i.e., Coverage with Evidence Development). Although the simulation studies and case study focus on clinical trials of ICD use in primary and secondary prevention of SCD, we highlight throughout this report how our findings are generalizable to other clinical domains.

The report ends with a series of conclusions based on our review of the literature, the simulation studies, and the case study.

## Bayesian Tutorial

### Background and Scope

The two main schools of statistical thought are Bayesian and frequentist. Although some statisticians strongly prefer one approach over the other, most are willing to consider both, and, indeed, with the increased feasibility of Bayesian computation, practice appears to be moving toward a blending of these perspectives. This tutorial takes no position on the ongoing debate about the foundations of statistics. Instead, its purpose is to provide non-technical background for non-statisticians.

For this purpose, it is critical to recognize that the current environment is based almost entirely on frequentist ideas. Some of this emphasis is historical based on when Bayesian techniques were more difficult to implement than is presently the case. The other reason for the emphasis on frequentist ideas is that this approach can be implemented in a highly rule-based fashion. This allows agreement on the ground rules for what will be deemed statistically significant before data analysis begins, and confidence that such ground rules will be consistent from application to application. While Bayesian analyses can be pre-specified and rule-based, they are generally flexible - advocates of the Bayesian approach cite this as an advantage.

This section does not focus on circumstances where the Bayesian approach yields similar results but frames the analysis differently, or on those situations where the Bayesian approach might provide marginal improvements over a frequentist approach. Recognizing the inherent limitations of non-technical tutorials, this section tries to provide answers to the following two questions:

1. For the purposes of policy makers, what are Bayesian statistics?
2. For the purposes of policy makers, what are the situations where the Bayesian approach is likely to be so much better than the frequentist approach that it should be strongly considered?

For a more comprehensive tutorial, we recommend the references cited in Chapter 3.

### Diagnostic Testing Example

Figure 1 illustrates the basic Bayesian paradigm, namely that “prior information and beliefs” plus “new data” yield “revised beliefs.” This paradigm can be illustrated by diagnostic testing.

Figure 1 Basic Bayesian paradigm

Suppose that the physician suspects that a patient might have meningitis, and is considering whether to subject that patient to the risk and expense of a diagnostic test that can shed additional light on the matter. After taking a history and performing a physical examination, the physician believes that the patient has a 20 percent probability of meningitis. This “20 percent” is the “prior information.”

Prior information can be entirely objective, entirely subjective, or a combination of the two. An example of entirely objective information is the use of a risk score – for example, if the patient has a fever in excess of 103 degrees Fahrenheit a risk score would increase. An example of entirely subjective information is the physician’s intuition based on years of experience but impossible to quantify using precise rules. Combining the two begins with the quantitative risk score, with clinical intuition being used to modify the score. Note that in this example the “subjective” assessment is in fact based on a lot of information (i.e., it is a holistic application of extensive medical knowledge); however, it is “subjective” in the sense that it cannot be reduced to a reproducible quantitative algorithm.

As a general principle, applications of Bayesian inference are relatively uncontroversial when the prior information is objective and reproducible. Applications of Bayesian inference where prior beliefs are subjective and not reproducible are more controversial. These applications become increasingly controversial when the role of the prior beliefs increases relative to the role of the data, and the more that prior probability is guided by intuition or is otherwise idiosyncratic.

Suppose that the physician decides to perform the diagnostic test, and that the test has 90 percent sensitivity and 80 percent specificity. Recall that sensitivity is the probability that a patient with meningitis will have a positive test corresponding to “meningitis,” and that specificity is the probability that a patient without meningitis will have a negative test corresponding to “not meningitis” (see Figure 2). We posit a population of 1000 patients, of whom 200 have meningitis because the prior probability of disease is 20 percent. Of these, 180 will have a positive test because the sensitivity is 90 percent. The remaining entries of the table are filled in similarly. The positive predictive value is the probability that a patient with a positive test will actually have meningitis – 180/(180+160) = 53 percent. Similarly, the negative predictive value is the probability that a patient with a negative test will not have meningitis – 640/(640+20) = 97 percent.

Figure 2 Diagnostic test –20% prior probability of disease

Translating Figure 2 into Bayesian terminology, the prior probability of meningitis is 20 percent. The new data are the results of the test. If the results of the test are positive, the posterior probability of meningitis is 53 percent. The data have caused the physician to revise her prior beliefs about the probability that the patient has meningitis upward, from 20 percent to 53 percent. A negative test would cause her to revise her prior beliefs about the probability that the patient has meningitis downward, from 20 percent to 3 percent.

Figure 3 illustrates the role of the physician’s prior probability in Bayesian inference. In this Figure, we explore the scenario when the physician’s probability of meningitis is only 10 percent. This prior probability might have dropped from 20 percent (Figure 2) to 10 percent (Figure 3) because a different patient is being assessed. If the prior probability of disease is based on subjective criteria, different physicians might have different prior estimates of the probability of meningitis, even for the same patient. The sensitivity and specificity are properties of the diagnostic test and remain the same, as in Figure 2. The only difference is that the prior probability of meningitis is smaller. A positive test now yields a posterior probability of meningitis of 33 percent, and a negative test yields a posterior probability of 1 percent. This illustrates the general principle that where you end in a Bayesian analysis often depends on where you start.

Figure 3 Diagnostic test –10% prior probability of disease

This example also illustrates one of the reasons that an analyst might select a Bayesian approach – namely, that the problem under consideration is a particularly good match for the Bayesian way of thinking.

### Meta-analysis Example

The diagnostic testing example is particularly simple, in part because considerations of precision have been ignored. In reality, although the physician’s best estimate of the prior probability of meningitis is 20 percent (i.e., 20 percent is a “point estimate”), in practice this estimate of 20 percent would not be absolutely precise. Perhaps the physician is comfortable with any probability within the range of 15 to 25 percent. The sensitivity of the test might not be exactly 90 percent – perhaps it was based on a study whose results are consistent with everything in the range of 88 to 92 percent. A similar phenomenon holds for specificity. For a positive test the posterior probability of meningitis will not be a point estimate of 53 percent, but instead will fall in a range centered at 53 percent.

To illustrate the role played by precision, consider the frequentist graphical presentation of a meta-analysis, as in Figure 4. We now assume that two placebo-controlled randomized trials have been performed, both of which have as their primary outcome the improvement in the intervention group in comparison with placebo in a continuous measure such as systolic blood pressure (SBP). Here, an improvement of 0 implies no impact of the intervention, whereas positive numbers suggest that the intervention is preferable to the placebo because it is associated with a greater reduction in SBP. As drawn, both studies favor the intervention by different amounts.

Figure 4 Meta-analysis of the results of 2 randomized trials

In Figure 4, study 1 is smaller than study 2, and has a wider confidence interval around the estimated effect of the intervention. The summary measure, derived from the meta-analysis, has two characteristics. First, it has a tighter confidence interval than either study, illustrating the gain in precision associated with combining information across the two studies. Second, the point estimate for the meta-analysis-derived summary measure is closer to that of study 2 than that of study 1, which reflects that study 2 is providing more data.

Figure 4 also illustrates the process of Bayesian analysis in the presence of imprecision. In the Bayesian paradigm, “study 1” represents the prior distribution of the impact of the intervention on SBP in a way that takes into account the precision associated with the analyst’s prior beliefs. “Study 2” represents the new data in a way that takes into account the precision associated with these data. “Summary” represents the posterior distribution of the impact of the intervention on SBP, taking into account prior beliefs, the data, and the imprecision associated with each.

The next set of figures illustrates the role played by the prior distribution in the conclusions of a Bayesian analysis. In Figure 5, the prior distribution is diffuse since the probability of the parameter being within a given interval is wide. This situation is essentially equivalent to a meta-analysis with a small first study. This will have little or no impact on the results, illustrated by the similarity between the posterior distribution and the data. Diffuse prior distributions that have little impact on the results are termed non-informative prior distributions. Bayesian analyses that use non-informative prior distributions are relatively uncontroversial because the impact of prior beliefs is trivial in comparison with the impact of the data and the conclusions of a Bayesian analysis using a non-informative prior distribution may be the same as to the conclusions derived by classical methods. Note that for a non-informative prior, the interval associated with the prior would be over the entire real line.

Figure 5 Non-informative prior distribution

Figure 6 illustrates another type of prior distribution. The confidence intervals associated with this distribution are narrower than in Figure 5 – the prior distribution has an impact on the results (the posterior distribution) and is “informative.” The prior distribution is conservative in that it assumes the intervention has no impact on SBP. – Distributions with similarly conservative assumptions are termed “skeptical” since the analyst is skeptical that the intervention has an impact. The result of using the skeptical prior distribution is that the posterior distribution is less extreme than the data, and that the point estimate of the impact of the intervention from the new data is “shrunk” toward the mean of the posterior distribution, in this case toward the null value of 0. Bayesian analyses that use skeptical prior distributions are relatively uncontroversial, if for no other reason than that the above idea of “shrinkage” is also well accepted within frequentist approaches to statistical inference.

Figure 6 Prior distribution is informative and skeptical

Figure 7 illustrates a prior distribution that is informative but not skeptical. The prior belief is that the intervention is highly effective. Because the analyst posited an effect that was stronger than the effect observed in the new data, the prior distribution pulls the posterior distribution away from the null value of 0. In other words, the analyst concludes that the impact of the intervention is stronger than implied by the new data when these new data are considered in isolation. Applications with non-skeptical prior distributions are controversial because of this phenomenon. Such applications are more controversial when the prior distribution is based on the subjective beliefs of the analyst, and are less controversial when the prior distribution is based on real data such as from another clinical trial.

Figure 7 Prior distribution is informative and not skeptical

An example of deriving the prior distribution objectively is to use the results of a previous meta-analysis. In this situation the posterior distribution from the previous meta-analysis becomes the prior distribution when new studies become available. The new studies update the meta-analysis. A “sequential meta-analysis” or “cumulative meta-analysis” is iterative, with each new study published in the literature inducing another round of updating.

Figure 8 illustrates the worst case for Bayesian analysis. There, the prior distribution is non-skeptical and illustrates strong beliefs in the efficacy of the intervention. (Here, it is implicitly assumed that these strong beliefs are primarily based on intuition, rather than objective information such as a previous meta-analysis). The data provide little contribution to the posterior distribution, which essentially recapitulates the prior beliefs of the analyst. There is almost universal agreement that applications like those illustrated in Figure 8 are inappropriate, except perhaps to document the lack of objective data about the phenomenon under study.

Figure 8 Prior distribution is non-skeptical and dominates the analysis

The differences between Figures 5 and 8 can help illustrate the circumstances in which Bayesian methods might most naturally be considered. In Figure 5, there are enough data to provide sound inference. It does not matter whether the analysis is Bayesian or not, although some analysts will select a Bayesian approach because of their philosophical beliefs, the easier interpretation of the results, or because the type of problem is a good fit for a Bayesian formulation.

In Figure 8, there are too little data to provide sound inference, and a Bayesian approach risks being too subjective by being primarily based on subjective belief rather than objective data. The most natural applications of Bayesian methodology fall somewhere in between. Some data are available, but not enough to draw strong conclusions in the absence of other information. An informative prior distribution can be supported, either because it is skeptical or because it is based on objective information.

### Technical Note on the Role of Distributions

The usual presentations of meta-analysis (e.g., Figure 4) or its conceptually equivalent Bayesian counterparts (e.g., Figures 5 to 8) gloss over some assumptions about the shape of the prior distribution and of the new data. Figure 9 presents the same information, but in a way that highlights the distributional assumptions that underlie the analysis. In particular, a typical meta-analysis such as is depicted in Figure 4 assumes that the distribution of the outcome within each study, perhaps after an appropriate transformation such as log-transformation, is Gaussian. If so, the analyst can rely on the mathematical result that the combination of Gaussian distributions is Gaussian, and be confident that the posterior distribution is Gaussian as well. The exact nature of this latter distribution (its center point and its spread) can be obtained directly from a formula.

Figure 9 Use of distributions

When distributions can be combined in this simple fashion they are termed “conjugate.” Various other pairs of conjugate distributions exist. When the distributions in question are not conjugate, often the posterior distribution must be derived using simulations, which may be technically complex to implement. Such simulations are where the reader will encounter terms such as “Gibbs sampler” or “Markov chain Monte Carlo (MCMC).” This report does not focus on the details of deriving posterior distributions.

### Technical Note on Fixed- and Random-Effects Models, Heterogeneity, and Interaction

Although this is not intended to be an in-depth tutorial on meta-analysis, it may be helpful to highlight some additional concepts that will be used in this report. Specifically, the meta-analysis literature makes the distinction between “fixed-effect” models and “random-effects” models. Loosely speaking, a fixed-effect model assumes that the efficacy of the intervention is identical from study to study, and that the primary goal of the meta-analysis is to estimate this single specific quantity. The analyst using a fixed-effect model will begin with a “test for heterogeneity” – in essence, a statistical test that allows the data to disprove the assumption that the efficacy of the intervention is similar across the studies. In contrast, a random-effects model assumes (based on the philosophical belief that most things involving human biology are heterogeneous) that efficacy differs from study to study, and posits that efficacy follows a statistical distribution and that a primary goal of the meta-analysis is to estimate the parameters (e.g., mean, standard deviation) of this distribution.

Our report uses two elements of the above. First, our simulations utilize both fixed-and random-effects models. It should be noted in this context that random-effects modeling is particularly felicitous within the Bayesian framework, but that random-effects modeling can also be implemented within a frequentist paradigm. Accordingly, any advantages of random-effects and related models should not be entirely attributed to the Bayesian way of thinking, although it should also be noted that the Bayesian approach does accommodate random-effects and related models particularly well.

Second, our report uses the closely related concepts of heterogeneity and statistical interaction. In the context of subgroup analysis, heterogeneity is equivalent to having different intervention effects for different subgroups – for example, a device that is more efficacious for patients aged 50 to 64 years than for patients aged 65 years and above. Statistical interaction is data-based evidence of heterogeneity – for example, a statistical test that demonstrates that the above difference in efficacy was observed within a particular study. In practice, decisionmakers often desire evidence of interactions that are both statistically significant and clinically meaningful. The distinction between the two is that a statistically significant interaction implies that there is some difference in efficacy between subgroups (i.e., that the difference in efficacy is different from 0), whereas a clinically important interaction implies that this difference is “large enough to matter” (e.g., suggests that different actions be taken in one subgroup versus another). With small sample sizes within subgroups it is often the case that tests for statistical interaction will have low power – there, the concern is that while there is no statistical evidence for interaction, the data might nevertheless be consistent with clinically important differences in the efficacy of the intervention across subgroups.

### Making Decisions Using Bayesian Analysis

Decisionmaking in any particular Bayesian analysis takes place by examining properties of the posterior distribution. As an example of using the posterior distribution to make inferences, if more than 95 percent of the area of the posterior distribution for the impact of an intervention on SBP falls in positive territory, the analyst is “95 percent confident” that the intervention is effective. Bayesian analysts refer to this as the 95 percent credible interval. The credible interval has a specified or subjective probability of containing the parameter of interest, given the observed data and the prior information. The best guess or point estimate for the magnitude of effectiveness might be the mean, median, or mode of this posterior distribution. The precision of the conclusions is derived from the spread of the posterior distribution or the length of the credible intervals.

In practice, analyses such as the above are then supplemented by an exploration of robustness – for example, in order to determine whether similar conclusions are obtained when the prior distribution is modified. The less skeptical and more informative the prior distribution, the more extensive should be the assessment of robustness.

### Two Illustrative Applications of Bayesian Methodology

The ideal application of Bayesian methodology occurs when there are some data, but not quite enough to draw sufficiently firm conclusions. Our report will focus on one such application – namely, subgroup analysis.

CMS might be interested in the performance of a medical device among patients aged 65 to 74 years. Most clinical trials of this device, however, are in patients aged 55 to 64 years. Some information is available on patients aged 65 to 74 years, but is insufficient to form firm conclusions. In other words, some data are available on patients aged 65 to 74, but not enough. The question becomes whether a Bayesian analysis might be performed, with the information from other age groups of patients providing the prior distribution that can then be combined with the data regarding patients aged 65 to 74.

Another natural application of Bayesian statistics is in the design and analysis of Phase 1 and Phase 2 clinical trials, especially those trials for which it is critical to make the most statistically efficient use of all possible information. One reason for doing so might be the testing of a promising therapy, albeit one with potentially devastating adverse events, in a condition that is uniformly fatal. It is usually assumed that both the efficacy of the intervention and the likelihood of adverse events increase with the dose, so the goal is to estimate the maximum tolerable dose (the maximum dose with an acceptable level of adverse events). The analyst wishes to do so in a way that exposes as few patients as possible to unsafe doses of the drug, while exposing as many patients as possible to the drug’s therapeutic doses.

These goals cannot be accomplished by treating each possible dosage level in isolation, if for no other reason than the information for each dose will be based on small sample sizes and thus will be unreliable. Instead, the analyst posits a dose-response function between the probability of an adverse event and the dose. By transforming the outcome variable using a “logit” transformation, a straight line is obtained that can be described with a slope and an intercept (see Figure 10, which is drawn to have a slope of 1 and an intercept of 0). The prior distribution for the slope and intercept are derived from similar drugs, previously tested patients, and biologically informed supposition if necessary. The outcome for each patient can then be used, in Bayesian fashion, to update the estimates of this slope and intercept, and data collection continues until this line and the maximum dose corresponding to the acceptable probability of adverse events implied by this line has been estimated with adequate precision. At each step in the process (e.g., for each new patient) the information to date can be used to assign the most statistically appropriate dosage level, which is the core idea behind Bayesian adaptive designs.

Figure 10 Dose-response curves

The take-home message of this second example is that early-phase testing is another circumstance that satisfies the condition of “some but not quite enough data” that suggests the use of Bayesian methods. This example also illustrates the general principle that Bayesian methods are not limited to data analysis, but can be used in study design as well.

### Differences between Bayesian and Frequentist Methods

Most elements of frequentist inference have Bayesian counterparts. The above example illustrated the Bayesian counterpart to the 95 percent confidence interval used by frequentist statisticians, namely, the 95 percent credible interval used by Bayesians. There are subtle differences between what these two types of interval represent; but in practice they are similarly applied.

It is not an exaggeration to claim that the only people who believe strongly that there are important differences between analogous Bayesian and frequentist concepts are those who are already strongly convinced that one is theoretically superior to the other. For example, a frequentist might object that estimating the prior distribution involves judgment, despite the fact that doing so is crucial to the Bayesian approach. Similarly, a Bayesian might object to the fact that frequentist methods do not explicitly describe prior beliefs, despite the fact that they are implicitly taken into account by frequentist methods. We recommend these assertions not be taken seriously, since most practicing statisticians do not strongly favor one methodology over the other. As Bayesian methods are becoming increasingly feasible from a computational perspective, various elements of the two approaches appear to be blending over time.

One way to think about the differences between the Bayesian and frequentist approaches is to recognize that all applications of statistics are limited by the act of inference – what we would like to do is to observe an entire population, often including its future members, but we are limited by having data on only a subset of that population. This inescapable constraint implies that any statistical analysis will have some objective components (the mathematical maneuvers applied to the observed data) and some subjective components (extrapolating the results of the observed data to the population under consideration).

Where the Bayesian and frequentist approaches to statistics differ is not in the amount of subjective judgment required but instead in where and how subjective judgment enters the analysis. In a Bayesian analysis, the subjective features enter formally and explicitly, primarily through the specification of the prior distribution and the choice of the model to be used in the analysis; or they enter the analysis in how characteristics of the posterior distribution will be summarized in order to arrive at conclusions. In a frequentist analysis, the subjective features also enter in the choice of the model to be used in the analysis. They enter informally, in the design of the clinical study and through the implicit weighting given to various individual results in drawing overall conclusions. Factors in this weighting include whether individual results were statistically significant at some p value or not, the magnitude of observed trends, the overall consistency of observed trends in light of biological plausibility and the previous literature, and so forth.

If this informal weighting procedure is performed thoughtfully, the flexibility of the frequentist approach represents a potential strength; if not, the flexibility represents a potential source for erroneous conclusions, bias, and other sources of mischief. Similarly, the formal and explicit specification of how conclusions will be drawn from the data and what is known to date are a potential strength of the Bayesian approach, but only in those circumstances where the problem at hand and the knowledge to date make it sensible to do so. Fortunately, the results of Bayesian and frequentist analyses are often substantially similar, especially if both are performed with care and insight.

### Summary

The primary goal of this tutorial is to provide non-statistical readers having no previous exposure to Bayesian methods with an intuitive introduction to those methods – specifically, “what Bayesian statistics are about and when I should care.” What Bayesian statistics are about is the process by which “prior beliefs are combined with new data in order to generate revised beliefs.” The primary strength of Bayesian statistics is its explicit nature – by specifying ahead of time and in detail what is currently known, and how decisions will be derived from the combination of this knowledge and the new data, analyses, and decisions that derive from those analyses will exhibit the laudable characteristic of transparency. Its primary weakness is that not all applications of statistics fit naturally into this paradigm.

When data have already been collected, there is only one set of circumstances where one should always strongly consider, independent of any philosophical preferences, the use of Bayesian approaches – namely, when: (a) a decision must be made; (b) some data are available, but the existing data provide insufficient guidance or precision for making that decision; and (c) additional information can be defensibly brought to bear on that decision. In this context, “defensible” could potentially mean: (a) based on related data such as a similar (but not identical) intervention applied to a similar but not identical population; (b) specified using conservative assumptions (e.g., such as an intervention having no impact on outcome); or (c) based on supposition, where the nature of that supposition is explicitly justified and accepted as reasonable by impartial observers.

When the study is in the design phase, the flexibility inherent in the Bayesian approach provides the basis for adaptive randomization, which allows the size of the study to be determined as data collection proceeds, and thus in some cases might help satisfy the ethical imperatives of exposing as few subjects as possible to risks and as many subjects as possible to treatments that are maximally beneficial.