# ICD Case Study

## Introduction

In this Appendix we detail for the interested reader the case study and our findings. More details will be available in a statistical manuscript. An executive summary of these findings are included in the full report.

Prior to the case study described in this section, we performed substantial simulation studies to demonstrate that while single trials may be adequately powered to detect main treatment effects, they often have low power to detect treatment-covariate interactions. Furthermore, these studies demonstrated that combining data from trials improves the power to detect such treatment-covariate interactions. Details about the simulation studies and our findings may be obtained from the authors and will be published in a statistical manuscript. To explore the findings from our simulation studies and to provide evidence concerning the advantages and disadvantages of Bayesian techniques in clinical trial design and analysis, we performed a case study of the use of ICD therapy in the prevention of SCD using data from eight clinical trials.

## Methods and Assumptions

For the purposes of this case study, we considered data from eight trials (AVID, CABG-PATCH, CASH, DEFINITE, MADIT-I, MADIT-II, MUSTT and SCD-HeFT). For any trial, the overall survival (in years from randomization) is the primary outcome. There are two treatment groups (ICD versus control) and four baseline prognostic variables, namely, age (in years), ejection fraction (given as a percentage), NYHA class (classes I through IV) and ischemic disease (yes/no). Data were analyzed according to the intention-to-treat. Moreover, we assumed that the four prognostic variables also capture differences in the trial designs. We omitted from our analysis patients who had missing entries in any of the above covariates.

Besides the clinical trial data, we received data from the CMS on the CMS ICD Registry patients representing patients who have had an ICD implanted and are requesting coverage from CMS. The data represent 121,398 implants between 12/31/2004 and 6/30/2007. We note, however, that the registry data are only on ICD patients; that is, there is no control group. Moreover, the registry does not currently have follow-up information regarding patients’ overall survival. Thus, for the purpose of illustration, we utilized registry data from the MUSTT study to address survival comparisons considering clinical trial and registry data.

### Analysis of Individual Trials

We utilized Cox-Proportional hazards and Weibull regression models to compare overall survival by treatment groups. An introductory text describing these types of survival models can be found here.91 The findings from these two models were qualitatively similar and so in our discussion here we only present those from the Weibull regression models. Although the Cox-Proportional hazards model is widely used, the Weibull regression model allows us to make comparisons of the estimation under Frequentist and Bayesian approaches on more similar modeling grounds. Details of the other models are available from the authors and will be published in a statistical manuscript.

First, we considered unadjusted analysis considering data from all patients in the trial as well as stratified analysis on subgroups. Second, we considered analysis that adjusted for the common set of baseline prognostic variables, both, with and without the interaction between each of the baseline prognostic variables and treatment.

### Analysis of Data Combining All Trials

We utilized Weibull regression models to compare overall survival by treatment groups in unadjusted and adjusted analysis. For the latter we considered models that included or not the interactions between baseline prognostic variables and treatment. To combine data from all trials we considered four model variations: 1) combining data from all trials, but without adjusting for (potential) trial effects; 2) combining data from all trials adjusting for trial effects assuming a fixed effect for trial; 3) combining data from all trials assuming a random effect for trial and 4) combining data from all trials assuming trial-specific baseline hazard functions. These models were estimated using maximum likelihood estimation.

Bayesian estimation was also performed in the above Weibull regression models. Moreover, we additionally considered a full hierarchical model utilizing random-effects for baseline hazard functions, main and interaction effects. We assumed normal priors for real-valued parameters (that is, parameters that can take on positive and negative values, such as the ICD effect). Precision parameters were assigned Gamma priors. Moreover, scale and shape parameters of the baseline hazard were assigned log-normal priors. Fixed effect parameters were assigned priors with mean zero and variance one. Random effects parameters were assigned priors with an overall population mean and population precision. Population means were assigned priors with mean zero and variance one, while precision parameters were assigned priors with mean and variance equal to one.

### Using Registry Data

We considered the random effects model (model 3 above) utilizing Bayesian estimation. This model formally accounts for the variability within and between trials. Using the posterior samples of the model parameters, we simulated the survival experience of hypothetical patients in a hypothetical new trial under the ICD and control groups in given prognostic subgroups. Using these samples we obtained the posterior predictive survival distributions for the ICD and control groups which can then be compared to the empirical survival distribution of the related subgroups in the registry data.

### Analysis of Aggregate versus Patient-level Data

One critical aspect of our analysis is the availability of patient-level data from ICD trials. In practice, however, data analysts may face a situation in which only aggregate data are available; for example, in the form of estimates of the treatment effect along with estimated standard errors. Moreover, such data become available sequentially as trial results get published. We, thus, performed additional analyses to investigate two additional points:

1. What are the implications of using aggregate data as opposed to using patient-level data in assessing overall ICD efficacy?
2. By considering the accumulated sequential evidence from trials, either using aggregate or patient-level data, would we be able to reach a conclusive decision of overall ICD efficacy sooner?

To answer the above questions, we considered fixed and random effects models and estimated these models under two different priors. Prior 2 has higher precision than prior 1. We set prior 2 to have different precisions when comparing the analysis for aggregate or patient-level data as we clarify below when we discuss our findings.

Finally, using patient-level data, we also considered the accumulated sequential evidence from trials to assess treatment-covariate interaction across prognostic subgroups.

All analyses were performed in R (version 2.7.2) and Winbugs (version 1.4.3). Convergence diagnosis of our Bayesian models was performed using the package BOA available in R. Additional details concerning the statistical models explored are available from the authors and will be published in a statistical manuscript.

## Findings

### Analysis of Individual Trials

Summary statistics for each trial by treatment group are shown in Appendix Table A1 (Parts 1 and 2). The table shows that the trials considered in this case study differ in sample size with the smallest trial having 196 patients (MADIT-I) and the largest with 1676 (SCD-HeFT) patients randomized to ICD and control. Moreover, participants have different compositions across trials. For example, some trials such as CABG-PATCH, MADIT-I, MADIT-II and MUSTT had only ischemic patients while the DEFINITE trial only included non-ischemic patients.

Appendix Table A1 – Part 1 Descriptive statistics for prognostic variables stratified by trial and treatment groups – (AVID, CABG-PATCH, CASH, and DEFINITE)^*^

Characteristic | | AVID | | CABG-PATCH | | CASH | | DEFINITE
Characteristic | | Control | ICD | Control | ICD | Control | ICD | Control | ICD
Number of Patients | | 509 | 507 | 454 | 446 | 189 | 99 | 229 | 229
Age | Mean (SD) | 65.33 (10.19) | 64.83 (10.82) | 64.95 (9.39) | 64.07 (9.21) | 57.83 (10.59) | 57.46 (11.18) | 58.11 (11.96) | 58.41 (13.84)
Age | < 65 | 215 (42.24%) | 229 (45.17%) | 227 (50.00%) | 223 (50.00%) | 145 (76.72%) | 72 (72.73%) | 153 (66.81%) | 148 (64.63%)
Age | [65,75) | 203 (39.88%) | 185 (36.49%) | 174 (38.33%) | 168 (37.67%) | 37 (19.58%) | 25 (25.25%) | 63 (27.51%) | 51 (22.27%)
Age | [75,85) | 86 (16.90% | 85 (16.77%) | 53 (11.67%) | 55 (12.33%) | 6 (3.17%) | 2 (2.02%) | 13 (5.68%) | 30 (13.10%)
Age | ≥ 85 | 5 (00.98%) | 8 (1.58%) | 0 | 0 | 1 (0.53%) | 0 | 0 | 0
Ejection Fraction | Mean (SD) | 30.82 (13.24) | 32.15 (13.46) | 27.05 (5.82) | 27.13 (5.75) | 45.18 (17.21) | 45.89 (19.51) | 21.84 (6.08) | 20.88 (5.93)
Ejection Fraction | ≤ 30% | 294 (58.22%) | 273 (54.17%) | 323 (71.15%) | 317 (71.08%) | 35 (20.47%) | 23 (24.21%) | 215 (93.89%) | 219 (95.63%)
Ejection Fraction | > 30% | 211 (32.76%) | 231 (45.83%) | 131 (28.85%) | 129 (28.92%) | 136 (79.53%) | 72 (75.79%) | 14 (6.11%) | 10 (4.37%)
Ischemic Disease | Yes | 433 (85.07%) | 435 (85.80%) | 454 (100.00%) | 446 (100.00%) | 167 (88.83%) | 88 (88.89%) | 0 | 0
Ischemic Disease | No | 76 (14.93%) | 72 (14.20%) | 0 | 0 | 21 (11.17%) | 11 (11.11%) | 229 (100.00%) | 229 (100.00%)
NYHA Class | I | 313 (61.49%) | 329 (64.89%) | 258 (56.95%) | 247 (55.88%) | 54 (29.35%) | 24 (24.49%) | 41 (17.90%) | 58 (25.33%)
NYHA Class | II | 136 (26.72%) | 144 (28.40%) | 85 (18.76%) | 87 (19.68%) | 106 (57.61%) | 56 (57.14%) | 139 (60.70%) | 124 (54.15%)
NYHA Class | III | 60 (11.79%) | 34 (6.71%) | 81 (17.88%) | 73 (16.52%) | 24 (13.04%) | 18 (18.37%) | 49 (21.40%) | 47 (20.52%)
NYHA Class | IV | 0 | 0 | 29 (6.40%) | 35 (7.92%) | 0 | 0 | 0 | 0

* Entries refer to means accompanied by standard deviations for continuous variables, or counts followed by percentages for categorical variables.

Abbreviations to Appendix Table A1 – Parts 1 and 2: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; ICD = implantable cardioverter defibrillator; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; SD = standard deviation

Appendix Table A1 – Part 2 Descriptive statistics for prognostic variables stratified by trial and treatment groups – (MADIT-I, MADIT-II, MUSTT, and SCD-HeFT)^*^

Characteristic | | MADIT-I | | MADIT-II | | MUSTT | | SCD-HeFT
Characteristic | | Control | ICD | Control | ICD | Control | ICD | Control | ICD
Number of Patients | | 101 | 95 | 490 | 742 | 353 | 167 | 847 | 829
Age | Mean (SD) | 63.8 (8.82) | 62.12 (8.73) | 64.57 (10.32) | 64.45 (10.45) | 64.87 (9.65) | 65.42 (8.52) | 58.58 (11.92) | 59.41 (11.87)
Age | < 65 | 49 (48.51%) | 53 (55.79%) | 228 (46.53%) | 345 (46.50%) | 162 (45.89%) | 72 (43.11%) | 563 (66.47%) | 535 (64.54%)
Age | [65,75) | 40 (39.60%) | 36 (37.89%) | 186 (37.96%) | 269 (36.25%) | 139 (39.38%) | 77 (46.11%) | 216 (25.50%) | 215 (25.93%)
Age | [75,85) | 12 (11.88%) | 6 (6.32%) | 69 (14.08%) | 123 (16.58%) | 50 (14.16%) | 18 (10.78%) | 64 (7.56%) | 76 (9.17%)
Age | ≥ 85 | 0 | 0 | 7 (1.43%) | 5 (0.67%) | 2 (0.57%) | 0 | 4 (0.47%) | 3 (0.36%)
Ejection Fraction | Mean (SD) | 24.57 (6.67) | 26.66 (6.50) | 23.16 (5.49) | 23.17 (5.42) | 27.65 (7.64) | 27.72 (7.91) | 25.71 (12.51) | 24.96 (12.76)
Ejection Fraction | ≤ 30% | 84 (83.17%) | 66 (69.47%) | 488 (99.59%) | 742 (100.00%) | 229 (64.87%) | 109 (65.27%) | 513 (60.57%) | 509 (61.40%)
Ejection Fraction | > 30% | 17 (16.83%) | 29 (30.53%) | 2 (0.41%) | 0 (0%) | 124 (35.13%) | 58 (34.73%) | 334 (39.43%) | 320 (38.60%)
Ischemic Disease | Yes | 101 (100.00%) | 95 (100.00%) | 490 (100.00%) | 742 (100.00%) | 353 (100.00%) | 167 (100.00%) | 453 (53.48%) | 431 (51.99%)
Ischemic Disease | No | 0 | 0 | 0 | 0 | 0 | 0 | 394 (46.52%) | 398 (48.01%)
NYHA Class | I | 33 (32.67%) | 36 (37.89%) | 187 (38.80%) | 256 (34.83%) | 71 (36.41%) | 38 (34.55%) | 0 | 0
NYHA Class | II | 50 (49.50%) | 44 (46.32%) | 165 (34.23%) | 259 (35.24%) | 75 (38.46%) | 43 (39.09%) | 594 (70.13%) | 566 (68.28%)
NYHA Class | III | 18 (17.82%) | 15 (15.79%) | 110 (22.82%) | 187 (25.44%) | 49 (25.13%) | 29 (29.36%) | 253 (29.87%) | 263 (31.72%)
NYHA Class | IV | 0 | 0 | 20 (4.15%) | 33 (4.49%) | 0 | 0 | 0 | 0

* Entries refer to means accompanied by standard deviations for continuous variables, or counts followed by percentages for categorical variables.

Abbreviations to Appendix Table A1 – Parts 1 and 2: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; ICD = implantable cardioverter defibrillator; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; SD = standard deviation

Appendix Figures A1(a) and A1(b) shows the Kaplan-Meier survival curves by trial and treatment group. In the analysis of individual trials, without adjusting for prognostic variables, there is evidence of treatment effect on overall survival in five trials (AVID, MADIT-I, MADIT-II, MUSTT and SCD-HeFT) (see Appendix Table A2). Among trials that showed treatment effect, the estimated hazard ratio (for death from all causes in the ICD group as compared to the control group) ranged from 0.35 to 0.75. Among trials that did not show treatment effect, the estimated hazard ratio ranged from 0.65 to 1.07.

Appendix Figure A1 (a) Kaplan-Meier survival curves by treatment group

Appendix Figure A1 (b) Kaplan-Meier survival curves by treatment group. (Note that in the SCD-HeFT trial the dotted red line corresponds to the “placebo” arm of the trial.)

Appendix Table A2 Comparison of overall survival by treatment group within each trial, unadjusted Cox-Proportional Hazards Model

Trial | Sample Size | | Number of Events | | Hazard Ratio | 95% CI | | P-value
Trial | Control | ICD | Control | ICD | Hazard Ratio | 95% CI | | P-value
AVID | 509 | 507 | 122 | 80 | 0.61 | 0.46 | 0.81 | < 0.001
CABG-PATCH | 454 | 446 | 95 | 101 | 1.07 | 0.81 | 1.42 | 0.635
CASH | 189 | 99 | 71 | 37 | 0.89 | 0.60 | 1.32 | 0.549
DEFINITE | 229 | 229 | 40 | 28 | 0.65 | 0.40 | 1.06 | 0.08
MADIT-I | 101 | 95 | 39 | 17 | 0.35 | 0.19 | 0.63 | < 0.001
MADIT-II | 490 | 742 | 105 | 107 | 0.65 | 0.50 | 0.85 | 0.002
MUSTT | 353 | 167 | 158 | 35 | 0.42 | 0.29 | 0.60 | < 0.001
SCD-HeFT | 847 | 829 | 284 | 182 | 0.75 | 0.62 | 0.91 | 0.004

Abbreviations for Appendix Table A2: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; CI = confidence interval; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; ICD = implantable cardioverter defibrillator; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Comparisons of overall survival by treatment group within prognostic subgroups in general failed to show an association between treatment and overall survival (see Appendix Table A3). Moreover, most entries in the table with significant results were no longer significant when considering Bonferroni’s adjustment to account for multiple testing. The only exception was in subgroup 4 (age < 65, EF < 30 percent, NYHA 2 and ischemic disease) in the SCD-HeFT trial (Bonferroni’s adjusted p-value < 0.001). We note that these results are affected by the small sample sizes in each subgroup (Appendix Table A4 [Parts 1–5]).

Appendix Table A3 Comparison of overall survival by treatment group within each trial, stratified analysis^*^

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | AVID | CABG- PATCH | CASH | DEFINITE | MADIT-I | MADIT-II | MUSTT | SCD- HeFT
1 | < 65 | ≤ 30% | 1 | Non-Isch | 0.29 (0.03, 2.37) | - | - | 0.58 (0.10, 3.45) | - | - | - | -
2 | < 65 | ≤ 30% | 1 | Isch | 0.65 (0.23, 1.79) | 0.54 (0.22, 1.36) | - | - | - | 0.66 (0.27, 1.62) | 0.79 (0.19, 3.32) | -
3 | < 65 | ≤ 30% | 2 | Non-Isch | 0.69 (0.04, 11.1) | - | - | 0.85 (0.34, 2.15) | - | - | - | 0.67 (0.35, 1.32)
4 | < 65 | ≤ 30% | 2 | Isch | 0.62 (0.21, 1.82) | 1.27 (0.46, 3.51) | 0.14 (0.03, 0.64) | - | 0.47 (0.12, 1.78) | 0.49 (0.19, 1.25) | 0.14 (0.02, 1.06) | 0.33 (0.17, 0.62)
5 | < 65 | ≤ 30% | 3 | Non-Isch | - | - | - | 0.49 (0.12, 2.04) | - | - | - | 0.95 (0.43, 2.10)
6 | < 65 | ≤ 30% | 3 | Isch | 0.51 (0.14, 1.87) | 0.84 (0.23, 3.16) | 5.88 (0.61, 56.9) | - | 0.46 (0.09, 2.38) | 0.81 (0.33, 1.94) | 0.92 (0.30, 2.83) | 0.71 (0.40, 1.29)
7 | < 65 | ≤ 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
8 | < 65 | ≤ 30% | 4 | Isch | - | 0.52 (0.12, 2.33) | - | - | - | 1.92 (0.36, 10.1) | - | -
9 | < 65 | > 30% | 1 | Non-Isch | - | - | - | - | - | - | - | -
10 | < 65 | > 30% | 1 | Isch | 1.03 (0.28, 3.82) | 0.81 (0.18, 3.63) | 0.37 (0.04, 3.08) | - | - | - | 2.00 (0.12, 32.9) | -
11 | < 65 | > 30% | 2 | Non-Isch | 0.80 (0.07, 8.90) | - | 0.50 (0.03, 8.46) | - | - | - | - | 1.04 (0.38, 2.87)
12 | < 65 | > 30% | 2 | Isch | 1.24 (0.11, 13.8) | - | 0.85 (0.34, 2.15) | - | 0.14 (0.01, 1.59) | - | - | 0.86 (0.40, 1.86)
13 | < 65 | > 30% | 3 | Non-Isch | - | - | - | - | - | - | - | 0.21 (0.02, 1.86)
14 | < 65 | > 30% | 3 | Isch | - | 0.91 (0.18, 4.50) | 1.42 (0.26, 7.80) | - | - | - | 0.47 (0.04, 5.35) | 1.60 (0.68, 3.81)
15 | < 65 | > 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
16 | < 65 | > 30% | 4 | Isch | - | - | - | - | - | - | - | -
17 | [65,75) | ≤ 30% | 1 | Non-Isch | - | - | - | 0.36 (0.04, 3.44) | - | - | - | -
18 | [65,75) | ≤ 30% | 1 | Isch | 0.65 (0.27, 1.57) | 0.98 (0.46, 2.07) | - | - | 0.45 (0.04, 5.02) | 0.49 (0.22, 1.06) | 0.61 (0.13, 2.93) | -
19 | [65,75) | ≤ 30% | 2 | Non-Isch | - | - | - | 1.24 (0.31, 4.98) | - | - | - | 0.76 (0.31, 1.87)
20 | [65,75) | ≤ 30% | 2 | Isch | 0.39 (0.12, 1.22) | 1.53 (0.58, 4.05) | 0.31 (0.03, 3.48) | - | 0.38 (0.11, 1.32) | 0.89 (0.42, 1.90) | 0.38 (0.10, 1.44) | 0.71 (0.36, 1.40)
21 | [65,75) | ≤ 30% | 3 | Non-Isch | - | - | - | 0.60 (0.15, 2.33) | - | - | - | 0.88 (0.37, 2.11)
22 | [65,75) | ≤ 30% | 3 | Isch | 0.33 (0.04, 2.76) | 1.28 (0.53, 3.10) | 1.09 (0.09, 13.3) | - | 0.23 (0.04, 1.32) | 0.29 (0.13, 0.68) | 0.14 (0.03, 0.64) | 1.42 (0.70, 2.86)
23 | [65,75) | ≤ 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
24 | [65,75) | ≤ 30% | 4 | Isch | - | - | - | - | - | 1.27 (0.33, 4.89) | - | -
25 | [65,75) | > 30% | 1 | Non-Isch | - | - | - | - | - | - | - | -
26 | [65,75) | > 30% | 1 | Isch | 0.83 (0.34, 2.00) | 1.01 (0.30, 3.34) | - | - | - | - | 1.60 (0.10, 25.7) | -
27 | [65,75) | > 30% | 2 | Non-Isch | - | - | - | - | - | - | - | 0.80 (0.19, 3.35)
28 | [65,75) | > 30% | 2 | Isch | 0.60 (0.13, 2.70) | 0.48 (0.04, 5.35) | 2.20 (0.55, 8.76) | - | - | - | - | 0.08 (0.01, 0.61)
29 | [65,75) | > 30% | 3 | Non-Isch | - | - | - | - | - | - | - | -
30 | [65,75) | > 30% | 3 | Isch | - | 0.27 (0.03, 2.64) | 2.14 (0.51, 9.08) | - | - | - | - | 2.46 (0.83, 7.23)
31 | [65,75) | > 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
32 | [65,75) | > 30% | 4 | Isch | - | 0.52 (0.09, 3.20) | - | - | - | - | - | -
33 | ≥ 75 | ≤ 30% | 1 | Non-Isch | - | | - | (0.18 0.03, 1.33) | - | | - | -
34 | ≥ 75 | ≤ 30% | 1 | Isch | 0.92 (0.29, 2.92) | 2.27 (0.47, 11.0) | - | - | - | 0.74 (0.27, 1.99) | 6.36 (0.38, 106) | -
35 | ≥ 75 | ≤ 30% | 2 | Non-Isch | 0.47 (0.03, 7.86) | - | - | 1.27 (0.12, 14.0) | - | - | - | 0.24 (0.03, 1.97)
36 | ≥ 75 | ≤ 30% | 2 | Isch | 1.03 (0.36, 2.98) | 2.31 (0.21, 25.5) | - | - | - | 0.26 (0.07, 0.99) | 0.85 (0.08, 9.44) | 0.15 (0.02, 1.16)
37 | ≥ 75 | ≤ 30% | 3 | Non-Isch | - | - | - | 0.11 (0.01, 1.10) | - | - | - | 0.18 (0.01, 2.93)
38 | ≥ 75 | ≤ 30% | 3 | Isch | 0.62 (0.06, 5.96) | 1.14 (0.40, 3.27) | - | - | - | 0.60 (0.27, 1.34) | - | 0.88 (0.33, 2.36)
39 | ≥ 75 | ≤ 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
40 | ≥ 75 | ≤ 30% | 4 | Isch | - | - | - | - | - | - | - | -
41 | ≥ 75 | > 30% | 1 | Non-Isch | - | - | - | - | - | - | - | -
42 | ≥ 75 | > 30% | 1 | Isch | 1.25 (0.35, 4.43) | 0.38 (0.04, 3.63) | - | - | - | - | - | -
43 | ≥ 75 | > 30% | 2 | Non-Isch | - | - | - | - | - | - | - | 0.39 (0.04, 3.52)
44 | ≥ 75 | > 30% | 2 | Isch | 1.08 (0.10, 11.9) | - | 0.84 (0.07, 9.61) | - | - | - | 3.47 (0.31, 38.4) | 0.75 (0.15, 3.70)
45 | ≥ 75 | > 30% | 3 | Non-Isch | - | - | - | - | - | - | - | -
46 | ≥ 75 | > 30% | 3 | Isch | - | - | - | - | - | - | - | -
47 | ≥ 75 | > 30% | 4 | Non-Isch | - | - | - | - | - | - | - | -
48 | ≥ 75 | > 30% | 4 | Isch | - | - | - | - | - | - | - | -

* For each cell, entries give estimated hazard ratio and 95% confidence interval (unadjusted for multiple testing) comparing survival by treatment in the subgroups of interest. Missing entries indicate unavailable data for the particular subgroup. Entries highlighted in red indicate significant results at the unadjusted significance level of 5%.

Abbreviations for Appendix Table A23: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Appendix Table A4 – Part 1 Subgroup composition by treatment group and trial – (all trials)

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | All Trials
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | Control | | ICD
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | #Subjects | #Events | #Subjects | #Events
1 | < 65 | ≤ 30% | 1 | Non-Isch | 45 | 9 | 42 | 3
2 | < 65 | ≤ 30% | 1 | Isch | 247 | 39 | 295 | 28
3 | < 65 | ≤ 30% | 2 | Non-Isch | 240 | 33 | 227 | 24
4 | < 65 | ≤ 30% | 2 | Isch | 306 | 96 | 302 | 40
5 | < 65 | ≤ 30% | 3 | Non-Isch | 92 | 21 | 82 | 17
6 | < 65 | ≤ 30% | 3 | Isch | 171 | 68 | 188 | 51
7 | < 65 | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0
8 | < 65 | ≤ 30% | 4 | Isch | 16 | 6 | 27 | 8
9 | < 65 | > 30% | 1 | Non-Isch | 15 | 3 | 9 | 1
10 | < 65 | > 30% | 1 | Isch | 173 | 15 | 156 | 10
11 | < 65 | > 30% | 2 | Non-Isch | 94 | 10 | 98 | 10
12 | < 65 | > 30% | 2 | Isch | 157 | 35 | 135 | 22
13 | < 65 | > 30% | 3 | Non-Isch | 23 | 6 | 30 | 1
14 | < 65 | > 30% | 3 | Isch | 58 | 19 | 50 | 19
15 | < 65 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0
16 | < 65 | > 30% | 4 | Isch | 2 | 0 | 6 | 1
17 | [65,75) | ≤ 30% | 1 | Non-Isch | 18 | 5 | 20 | 1
18 | [65,75) | ≤ 30% | 1 | Isch | 222 | 53 | 211 | 34
19 | [65,75) | ≤ 30% | 2 | Non-Isch | 74 | 14 | 78 | 14
20 | [65,75) | ≤ 30% | 2 | Isch | 198 | 64 | 249 | 61
21 | [65,75) | ≤ 30% | 3 | Non-Isch | 37 | 17 | 32 | 15
22 | [65,75) | ≤ 30% | 3 | Isch | 128 | 65 | 133 | 49
23 | [65,75) | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0
24 | [65,75) | ≤ 30% | 4 | Isch | 20 | 4 | 24 | 8
25 | [65,75) | > 30% | 1 | Non-Isch | 4 | 3 | 3 | 0
26 | [65,75) | > 30% | 1 | Isch | 98 | 17 | 101 | 16
27 | [65,75) | > 30% | 2 | Non-Isch | 21 | 5 | 19 | 4
28 | [65,75) | > 30% | 2 | Isch | 110 | 35 | 74 | 8
29 | [65,75) | > 30% | 3 | Non-Isch | 13 | 1 | 7 | 2
30 | [65,75) | > 30% | 3 | Isch | 37 | 17 | 33 | 16
31 | [65,75) | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0
32 | [65,75) | > 30% | 4 | Isch | 5 | 3 | 4 | 2
33 | ≥ 75 | ≤ 30% | 1 | Non-Isch | 3 | 2 | 12 | 3
34 | ≥ 75 | ≤ 30% | 1 | Isch | 80 | 21 | 92 | 22
35 | ≥ 75 | ≤ 30% | 2 | Non-Isch | 20 | 8 | 22 | 4
36 | ≥ 75 | ≤ 30% | 2 | Isch | 77 | 28 | 76 | 16
37 | ≥ 75 | ≤ 30% | 3 | Non-Isch | 5 | 4 | 16 | 3
38 | ≥ 75 | ≤ 30% | 3 | Isch | 67 | 35 | 78 | 33
39 | ≥ 75 | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0
40 | ≥ 75 | ≤ 30% | 4 | Isch | 6 | 1 | 7 | 3
41 | ≥ 75 | > 30% | 1 | Non-Isch | 2 | 0 | 1 | 1
42 | ≥ 75 | > 30% | 1 | Isch | 42 | 8 | 43 | 7
43 | ≥ 75 | > 30% | 2 | Non-Isch | 7 | 4 | 4 | 1
44 | ≥ 75 | > 30% | 2 | Isch | 34 | 10 | 36 | 8
45 | ≥ 75 | > 30% | 3 | Non-Isch | 3 | 1 | 6 | 0
46 | ≥ 75 | > 30% | 3 | Isch | 10 | 5 | 11 | 5
47 | ≥ 75 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0
48 | ≥ 75 | > 30% | 4 | Isch | 0 | 0 | 0 | 0

Abbreviations for Appendix Table A4 – Parts 1–5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ICD = implantable cardioverter defibrillator; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Appendix Table A4 – Part 2 Subgroup composition by treatment group and trial – (AVID and CABG-PATCH)

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | AVID | | | | CABG-PATCH
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | Control | | ICD | | Control | | ICD
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events
1 | < 65 | ≤ 30% | 1 | Non-Isch | 16 | 6 | 8 | 1 | 0 | 0 | 0 | 0
2 | < 65 | ≤ 30% | 1 | Isch | 38 | 7 | 62 | 8 | 84 | 13 | 83 | 7
3 | < 65 | ≤ 30% | 2 | Non-Isch | 9 | 1 | 14 | 1 | 0 | 0 | 0 | 0
4 | < 65 | ≤ 30% | 2 | Isch | 31 | 11 | 28 | 5 | 35 | 7 | 34 | 8
5 | < 65 | ≤ 30% | 3 | Non-Isch | 9 | 0 | 4 | 2 | 0 | 0 | 0 | 0
6 | < 65 | ≤ 30% | 3 | Isch | 15 | 10 | 8 | 3 | 28 | 5 | 24 | 6
7 | < 65 | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8 | < 65 | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 8 | 4 | 12 | 3
9 | < 65 | > 30% | 1 | Non-Isch | 7 | 0 | 5 | 0 | 0 | 0 | 0 | 0
10 | < 65 | > 30% | 1 | Isch | 72 | 4 | 78 | 5 | 47 | 4 | 43 | 3
11 | < 65 | > 30% | 2 | Non-Isch | 5 | 2 | 5 | 1 | 0 | 0 | 0 | 0
12 | < 65 | > 30% | 2 | Isch | 11 | 1 | 13 | 2 | 12 | 1 | 8 | 0
13 | < 65 | > 30% | 3 | Non-Isch | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
14 | < 65 | > 30% | 3 | Isch | 2 | 1 | 2 | 0 | 10 | 3 | 11 | 3
15 | < 65 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16 | < 65 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 2 | 0 | 6 | 1
17 | [65,75) | ≤ 30% | 1 | Non-Isch | 10 | 2 | 10 | 0 | 0 | 0 | 0 | 0
18 | [65,75) | ≤ 30% | 1 | Isch | 56 | 13 | 53 | 8 | 74 | 16 | 57 | 12
19 | [65,75) | ≤ 30% | 2 | Non-Isch | 5 | 0 | 7 | 1 | 0 | 0 | 0 | 0
20 | [65,75) | ≤ 30% | 2 | Isch | 31 | 11 | 24 | 4 | 21 | 6 | 30 | 13
21 | [65,75) | ≤ 30% | 3 | Non-Isch | 3 | 0 | 1 | 1 | 0 | 0 | 0 | 0
22 | [65,75) | ≤ 30% | 3 | Isch | 16 | 7 | 5 | 1 | 23 | 9 | 21 | 11
23 | [65,75) | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
24 | [65,75) | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 10 | 0 | 12 | 3
25 | [65,75) | > 30% | 1 | Non-Isch | 3 | 2 | 3 | 0 | 0 | 0 | 0 | 0
26 | [65,75) | > 30% | 1 | Isch | 52 | 11 | 52 | 9 | 28 | 5 | 31 | 6
27 | [65,75) | > 30% | 2 | Non-Isch | 0 | 0 | 4 | 0 | 0 | 0 | 0 | 0
28 | [65,75) | > 30% | 2 | Isch | 19 | 4 | 21 | 3 | 8 | 2 | 7 | 1
29 | [65,75) | > 30% | 3 | Non-Isch | 2 | 0 | 1 | 1 | 0 | 0 | 0 | 0
30 | [65,75) | > 30% | 3 | Isch | 2 | 1 | 3 | 0 | 5 | 3 | 4 | 1
31 | [65,75) | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
32 | [65,75) | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 5 | 3 | 4 | 2
33 | ≥ 75 | ≤ 30% | 1 | Non-Isch | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0
34 | ≥ 75 | ≤ 30% | 1 | Isch | 27 | 7 | 23 | 5 | 12 | 2 | 21 | 7
35 | ≥ 75 | ≤ 30% | 2 | Non-Isch | 2 | 1 | 4 | 1 | 0 | 0 | 0 | 0
36 | ≥ 75 | ≤ 30% | 2 | Isch | 17 | 9 | 14 | 6 | 8 | 1 | 7 | 4
37 | ≥ 75 | ≤ 30% | 3 | Non-Isch | 0 | 0 | 3 | 1 | 0 | 0 | 0 | 0
38 | ≥ 75 | ≤ 30% | 3 | Isch | 8 | 3 | 4 | 1 | 15 | 7 | 12 | 7
39 | ≥ 75 | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
40 | ≥ 75 | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 4 | 1 | 1 | 0
41 | ≥ 75 | > 30% | 1 | Non-Isch | 2 | 0 | 1 | 1 | 0 | 0 | 0 | 0
42 | ≥ 75 | > 30% | 1 | Isch | 25 | 4 | 30 | 6 | 13 | 3 | 12 | 1
43 | ≥ 75 | > 30% | 2 | Non-Isch | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0
44 | ≥ 75 | > 30% | 2 | Isch | 5 | 1 | 10 | 2 | 1 | 0 | 1 | 1
45 | ≥ 75 | > 30% | 3 | Non-Isch | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0
46 | ≥ 75 | > 30% | 3 | Isch | 2 | 1 | 2 | 0 | 0 | 0 | 1 | 1
47 | ≥ 75 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
48 | ≥ 75 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

Abbreviations for Appendix Table A4 – Parts 1–5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ICD = implantable cardioverter defibrillator; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Appendix Table A4 – Part 3 Subgroup composition by treatment group and trial – (CASH and DEFINITE)

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | CASH | | | | DEFINITE
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | Control | | ICD | | Control | | ICD
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events
1 | < 65 | ≤ 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 29 | 3 | 34 | 2
2 | < 65 | ≤ 30% | 1 | Isch | 3 | 1 | 1 | 1 | 0 | 0 | 0 | 0
3 | < 65 | ≤ 30% | 2 | Non-Isch | 1 | 0 | 2 | 1 | 89 | 10 | 78 | 8
4 | < 65 | ≤ 30% | 2 | Isch | 16 | 11 | 9 | 2 | 0 | 0 | 0 | 0
5 | < 65 | ≤ 30% | 3 | Non-Isch | 2 | 2 | 1 | 0 | 24 | 5 | 29 | 3
6 | < 65 | ≤ 30% | 3 | Isch | 5 | 2 | 5 | 4 | 0 | 0 | 0 | 0
7 | < 65 | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8 | < 65 | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
9 | < 65 | > 30% | 1 | Non-Isch | 7 | 3 | 1 | 0 | 1 | 0 | 3 | 1
10 | < 65 | > 30% | 1 | Isch | 39 | 6 | 17 | 1 | 0 | 0 | 0 | 0
11 | < 65 | > 30% | 2 | Non-Isch | 5 | 1 | 4 | 1 | 8 | 0 | 2 | 0
12 | < 65 | > 30% | 2 | Isch | 45 | 13 | 26 | 7 | 0 | 0 | 0 | 0
13 | < 65 | > 30% | 3 | Non-Isch | 1 | 1 | 0 | 0 | 2 | 1 | 2 | 0
14 | < 65 | > 30% | 3 | Isch | 4 | 2 | 5 | 4 | 0 | 0 | 0 | 0
15 | < 65 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16 | < 65 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
17 | [65,75) | ≤ 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 8 | 3 | 10 | 1
18 | [65,75) | ≤ 30% | 1 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
19 | [65,75) | ≤ 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 34 | 4 | 30 | 4
20 | [65,75) | ≤ 30% | 2 | Isch | 3 | 2 | 4 | 3 | 0 | 0 | 0 | 0
21 | [65,75) | ≤ 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 18 | 7 | 9 | 3
22 | [65,75) | ≤ 30% | 3 | Isch | 4 | 3 | 1 | 1 | 0 | 0 | 0 | 0
23 | [65,75) | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
24 | [65,75) | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25 | [65,75) | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0
26 | [65,75) | > 30% | 1 | Isch | 1 | 0 | 5 | 0 | 0 | 0 | 0 | 0
27 | [65,75) | > 30% | 2 | Non-Isch | 0 | 0 | 1 | 1 | 1 | 0 | 2 | 0
28 | [65,75) | > 30% | 2 | Isch | 19 | 8 | 5 | 3 | 0 | 0 | 0 | 0
29 | [65,75) | > 30% | 3 | Non-Isch | 1 | 1 | 0 | 0 | 1 | 0 | 0 | 0
30 | [65,75) | > 30% | 3 | Isch | 5 | 5 | 6 | 5 | 0 | 0 | 0 | 0
31 | [65,75) | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
32 | [65,75) | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
33 | ≥ 75 | ≤ 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 2 | 2 | 11 | 3
34 | ≥ 75 | ≤ 30% | 1 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
35 | ≥ 75 | ≤ 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 7 | 1 | 11 | 2
36 | ≥ 75 | ≤ 30% | 2 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
37 | ≥ 75 | ≤ 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 4 | 3 | 7 | 1
38 | ≥ 75 | ≤ 30% | 3 | Isch | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0
39 | ≥ 75 | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
40 | ≥ 75 | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
41 | ≥ 75 | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
42 | ≥ 75 | > 30% | 1 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
43 | ≥ 75 | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0
44 | ≥ 75 | > 30% | 2 | Isch | 5 | 2 | 2 | 1 | 0 | 0 | 0 | 0
45 | ≥ 75 | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
46 | ≥ 75 | > 30% | 3 | Isch | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0
47 | ≥ 75 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
48 | ≥ 75 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

Abbreviations for Appendix Table A4 – Parts 1–5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ICD = implantable cardioverter defibrillator; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Appendix Table A4 – Part 4 Subgroup composition by treatment group and trial – (MADIT-I and MADIT-II)

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | MADIT-I | | | | MADIT-II
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | Control | | ICD | | Control | | ICD
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events
1 | < 65 | ≤ 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
2 | < 65 | ≤ 30% | 1 | Isch | 14 | 3 | 12 | 0 | 91 | 10 | 124 | 9
3 | < 65 | ≤ 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
4 | < 65 | ≤ 30% | 2 | Isch | 21 | 8 | 15 | 3 | 81 | 10 | 115 | 8
5 | < 65 | ≤ 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
6 | < 65 | ≤ 30% | 3 | Isch | 9 | 5 | 7 | 2 | 44 | 8 | 87 | 13
7 | < 65 | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8 | < 65 | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 8 | 2 | 15 | 5
9 | < 65 | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
10 | < 65 | > 30% | 1 | Isch | 2 | 0 | 11 | 0 | 1 | 0 | 0 | 0
11 | < 65 | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
12 | < 65 | > 30% | 2 | Isch | 3 | 2 | 7 | 1 | 0 | 0 | 0 | 0
13 | < 65 | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
14 | < 65 | > 30% | 3 | Isch | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0
15 | < 65 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16 | < 65 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
17 | [65,75) | ≤ 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
18 | [65,75) | ≤ 30% | 1 | Isch | 7 | 2 | 7 | 1 | 67 | 15 | 86 | 11
19 | [65,75) | ≤ 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
20 | [65,75) | ≤ 30% | 2 | Isch | 16 | 7 | 17 | 6 | 60 | 11 | 107 | 17
21 | [65,75) | ≤ 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
22 | [65,75) | ≤ 30% | 3 | Isch | 6 | 4 | 6 | 3 | 46 | 19 | 62 | 8
23 | [65,75) | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
24 | [65,75) | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 10 | 4 | 12 | 5
25 | [65,75) | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26 | [65,75) | > 30% | 1 | Isch | 5 | 0 | 5 | 0 | 0 | 0 | 0 | 0
27 | [65,75) | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
28 | [65,75) | > 30% | 2 | Isch | 5 | 1 | 0 | 0 | 0 | 0 | 0 | 0
29 | [65,75) | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
30 | [65,75) | > 30% | 3 | Isch | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 0
31 | [65,75) | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
32 | [65,75) | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
33 | ≥ 75 | ≤ 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
34 | ≥ 75 | ≤ 30% | 1 | Isch | 4 | 3 | 0 | 0 | 28 | 7 | 46 | 9
35 | ≥ 75 | ≤ 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
36 | ≥ 75 | ≤ 30% | 2 | Isch | 5 | 1 | 2 | 0 | 23 | 7 | 37 | 3
37 | ≥ 75 | ≤ 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
38 | ≥ 75 | ≤ 30% | 3 | Isch | 2 | 2 | 0 | 0 | 20 | 10 | 38 | 16
39 | ≥ 75 | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
40 | ≥ 75 | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 2 | 0 | 6 | 3
41 | ≥ 75 | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
42 | ≥ 75 | > 30% | 1 | Isch | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0
43 | ≥ 75 | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
44 | ≥ 75 | > 30% | 2 | Isch | 0 | 0 | 3 | 0 | 1 | 1 | 0 | 0
45 | ≥ 75 | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
46 | ≥ 75 | > 30% | 3 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
47 | ≥ 75 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
48 | ≥ 75 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

Abbreviations for Appendix Table A4 – Parts 1–5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ICD = implantable cardioverter defibrillator; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Appendix Table A4 – Part 5 Subgroup composition by treatment group and trial – (MUSTT and SCD-HeFT)

Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | MUSTT | | | | SCD-HeFT
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | Control | | ICD | | Control | | ICD
Sub- groups | Age | EF | NYHA | Isch/ Non-Isch | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events | #Subjects | #Events
1 | < 65 | ≤ 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
2 | < 65 | ≤ 30% | 1 | Isch | 17 | 5 | 13 | 3 | 0 | 0 | 0 | 0
3 | < 65 | ≤ 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 141 | 22 | 133 | 14
4 | < 65 | ≤ 30% | 2 | Isch | 24 | 13 | 10 | 1 | 98 | 36 | 91 | 13
5 | < 65 | ≤ 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 57 | 14 | 48 | 12
6 | < 65 | ≤ 30% | 3 | Isch | 15 | 9 | 10 | 5 | 55 | 29 | 47 | 18
7 | < 65 | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
8 | < 65 | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
9 | < 65 | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
10 | < 65 | > 30% | 1 | Isch | 12 | 1 | 7 | 1 | 0 | 0 | 0 | 0
11 | < 65 | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 76 | 7 | 87 | 8
12 | < 65 | > 30% | 2 | Isch | 8 | 4 | 7 | 0 | 78 | 14 | 74 | 12
13 | < 65 | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 20 | 4 | 27 | 1
14 | < 65 | > 30% | 3 | Isch | 4 | 2 | 3 | 1 | 38 | 11 | 28 | 10
15 | < 65 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
16 | < 65 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
17 | [65,75) | ≤ 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
18 | [65,75) | ≤ 30% | 1 | Isch | 18 | 7 | 8 | 2 | 0 | 0 | 0 | 0
19 | [65,75) | ≤ 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 35 | 10 | 41 | 9
20 | [65,75) | ≤ 30% | 2 | Isch | 18 | 8 | 14 | 3 | 49 | 19 | 53 | 15
21 | [65,75) | ≤ 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 16 | 10 | 22 | 11
22 | [65,75) | ≤ 30% | 3 | Isch | 13 | 11 | 8 | 2 | 20 | 12 | 30 | 23
23 | [65,75) | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
24 | [65,75) | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
25 | [65,75) | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
26 | [65,75) | > 30% | 1 | Isch | 12 | 1 | 8 | 1 | 0 | 0 | 0 | 0
27 | [65,75) | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 20 | 5 | 12 | 3
28 | [65,75) | > 30% | 2 | Isch | 11 | 3 | 7 | 0 | 48 | 17 | 34 | 1
29 | [65,75) | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 9 | 0 | 6 | 1
30 | [65,75) | > 30% | 3 | Non-Isch | 5 | 2 | 2 | 0 | 19 | 5 | 17 | 10
31 | [65,75) | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
32 | [65,75) | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
33 | ≥ 75 | ≤ 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
34 | ≥ 75 | ≤ 30% | 1 | Isch | 9 | 2 | 2 | 1 | 0 | 0 | 0 | 0
35 | ≥ 75 | ≤ 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 11 | 6 | 7 | 1
36 | ≥ 75 | ≤ 30% | 2 | Isch | 6 | 2 | 4 | 1 | 18 | 8 | 12 | 2
37 | ≥ 75 | ≤ 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 1 | 1 | 6 | 1
38 | ≥ 75 | ≤ 30% | 3 | Isch | 9 | 5 | 5 | 0 | 12 | 7 | 19 | 9
39 | ≥ 75 | ≤ 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
40 | ≥ 75 | ≤ 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
41 | ≥ 75 | > 30% | 1 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
42 | ≥ 75 | > 30% | 1 | Isch | 3 | 1 | 0 | 0 | 0 | 0 | 0 | 0
43 | ≥ 75 | > 30% | 2 | Non-Isch | 0 | 0 | 0 | 0 | 6 | 4 | 3 | 1
44 | ≥ 75 | > 30% | 2 | Isch | 8 | 3 | 1 | 1 | 14 | 3 | 19 | 3
45 | ≥ 75 | > 30% | 3 | Non-Isch | 0 | 0 | 0 | 0 | 2 | 0 | 6 | 0
46 | ≥ 75 | > 30% | 3 | Isch | 3 | 3 | 1 | 0 | 4 | 0 | 7 | 4
47 | ≥ 75 | > 30% | 4 | Non-Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
48 | ≥ 75 | > 30% | 4 | Isch | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

Abbreviations for Appendix Table A4 – Parts 1–5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ICD = implantable cardioverter defibrillator; Isch = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; Non-Isch = non-ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

To adjust for prognostic variables, we utilized the Weibull regression model. The model demonstrates evidence of treatment effect on overall survival in the trials previously identified as well as in the DEFINITE trial (Appendix Tables A5–A12). We also fitted Weibull regression models including the interaction between treatment and each of the prognostic variables. In general, there was no evidence of significant interactions. The exception was in CASH which showed significant treatment interaction with EF and NYHA class, MADIT 1 with a significant interaction between treatment and EF and SCD-HeFT with a significant interaction between treatment and AGE and NYHA class.

Appendix Table A5 Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from Weibull regression models fit to the AVID trial

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.43 | 0.15 | 0.00 | −0.36 | 0.49 | 0.46
AGE [65,75) | 0.30 | 0.17 | 0.07 | 0.32 | 0.21 | 0.13
AGE ≥ 75 | 0.64 | 0.19 | 0.00 | 0.46 | 0.25 | 0.06
EF > 30% | −0.51 | 0.16 | 0.00 | −0.62 | 0.21 | 0.00
NYHA II | 0.47 | 0.16 | 0.00 | 0.54 | 0.21 | 0.01
NYHA III | 0.98 | 0.21 | 0.00 | 1.02 | 0.25 | 0.00
NYHA IV | - | - | - | - | - | -
ISCH | 0.31 | 0.22 | 0.14 | 0.37 | 0.28 | 0.19
TRT*AGE [65,75) | - | - | - | −0.05 | 0.34 | 0.89
TRT*AGE ≥ 75 | - | - | - | 0.44 | 0.38 | 0.25
TRT*EF > 30% | - | - | - | 0.24 | 0.32 | 0.45
TRT*NYHA II | - | - | - | −0.21 | 0.33 | 0.53
TRT*NYHA III | - | - | - | −0.19 | 0.44 | 0.67
TRT*NYHA IV | - | - | - | - | - | -
TRT*ISCH | - | - | - | −0.17 | 0.44 | 0.69

Abbreviations for Appendix Table A5: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SE = standard error; TRT = treatment

Appendix Table A6 Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from Weibull regression models fit to the CABG-PATCH trial

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | 0.09 | 0.14 | 0.53 | −0.27 | 0.32 | 0.40
AGE [65,75) | 0.64 | 0.16 | 0.00 | 0.49 | 0.23 | 0.03
AGE ≥ 75 | 0.71 | 0.21 | 0.00 | 0.38 | 0.32 | 0.23
EF > 30% | −0.25 | 0.17 | 0.16 | −0.08 | 0.24 | 0.75
NYHA II | 0.55 | 0.19 | 0.00 | 0.25 | 0.29 | 0.39
NYHA III | 0.93 | 0.18 | 0.00 | 0.87 | 0.25 | 0.00
NYHA IV | 0.53 | 0.27 | 0.05 | 0.49 | 0.39 | 0.21
ISCH | - | - | - | - | - | -
TRT*AGE [65,75) | - | - | - | 0.31 | 0.32 | 0.34
TRT*AGE ≥ 75 | - | - | - | 0.63 | 0.43 | 0.14
TRT*EF > 30% | - | - | - | −0.33 | 0.35 | 0.35
TRT*NYHA II | - | - | - | 0.54 | 0.39 | 0.16
TRT*NYHA III | - | - | - | 0.15 | 0.36 | 0.67
TRT*NYHA IV | - | - | - | 0.15 | 0.54 | 0.78
TRT*ISCH | - | - | - | - | - | -

Abbreviations for Appendix Table A6: CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SE = standard error; TRT = treatment

Appendix Table A7 Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from Weibull regression models fit to the CASH trial

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.13 | 0.21 | 0.55 | −3.21 | 1.17 | 0.01
AGE [65,75) | 0.64 | 0.23 | 0.00 | 0.48 | 0.30 | 0.10
AGE ≥ 75 | 0.88 | 0.48 | 0.07 | 1.11 | 0.55 | 0.04
EF > 30% | −0.16 | 0.25 | 0.51 | −0.64 | 0.33 | 0.05
NYHA II | 0.70 | 0.33 | 0.03 | 0.58 | 0.38 | 0.13
NYHA III | 1.74 | 0.38 | 0.00 | 1.08 | 0.48 | 0.02
NYHA IV | - | - | - | - | - | -
ISCH | −0.23 | 0.33 | 0.49 | −0.74 | 0.39 | 0.06
TRT*AGE [65,75) | - | - | - | 0.77 | 0.47 | 0.10
TRT*AGE ≥ 75 | - | - | - | −0.50 | 1.18 | 0.67
TRT*EF > 30% | - | - | - | 1.06 | 0.50 | 0.04
TRT*NYHA II | - | - | - | 0.97 | 0.84 | 0.25
TRT*NYHA III | - | - | - | 2.06 | 0.92 | 0.03
TRT*NYHA IV | - | - | - | - | - | -
TRT*ISCH | - | - | - | 1.06 | 0.73 | 0.15

Abbreviations for Appendix Table A7: CASH = Cardiac Arrest Study Hamburg trial; EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SE = standard error; TRT = treatment

Appendix Table A8 Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from Weibull regression models fit to the DEFINITE trial

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.58 | 0.26 | 0.03 | −0.62 | 0.56 | 0.26
AGE [65,75) | 0.43 | 0.28 | 0.12 | 0.38 | 0.35 | 0.28
AGE ≥ 75 | 1.16 | 0.35 | 0.00 | 1.68 | 0.48 | 0.00
EF > 30% | −0.08 | 0.59 | 0.89 | 0.06 | 0.73 | 0.93
NYHA II | −0.22 | 0.32 | 0.50 | −0.54 | 0.42 | 0.20
NYHA III | 0.60 | 0.33 | 0.07 | 0.74 | 0.42 | 0.08
NYHA IV | - | - | - | - | - | -
ISCH | - | - | - | - | - | -
TRT*AGE [65,75) | - | - | - | 0.09 | 0.57 | 0.88
TRT*AGE ≥ 75 | - | - | - | −0.82 | 0.68 | 0.23
TRT*EF > 30% | - | - | - | −0.30 | 1.26 | 0.81
TRT*NYHA II | - | - | - | 0.71 | 0.63 | 0.26
TRT*NYHA III | - | - | - | −0.41 | 0.68 | 0.55
TRT*NYHA IV | - | - | - | - | - | -
TRT*ISCH | - | - | - | - | - | -

Abbreviations for Appendix Table A8: DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SE = standard error; TRT = treatment

Appendix Table A9 Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from Weibull regression models fit to the MADIT-I trial

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.87 | 0.30 | 0.00 | −2.19 | 1.16 | 0.06
AGE [65,75) | 0.61 | 0.29 | 0.04 | 0.59 | 0.38 | 0.11
AGE ≥ 75 | 0.71 | 0.46 | 0.13 | 0.81 | 0.48 | 0.09
EF > 30% | −0.67 | 0.45 | 0.13 | −0.59 | 0.57 | 0.30
NYHA II | 0.56 | 0.39 | 0.15 | 0.22 | 0.43 | 0.60
NYHA III | 1.48 | 0.42 | 0.00 | 1.26 | 0.47 | 0.01
NYHA IV | - | - | - | - | - | -
ISCH | - | - | - | - | - | -
TRT*AGE [65,75) | - | - | - | 0.02 | 0.63 | 0.97
TRT*AGE ≥ 75 | - | - | - | −12.79 | 647.85 | 0.98
TRT*EF > 30% | - | - | - | 0.21 | 0.97 | 0.83
TRT*NYHA II | - | - | - | 1.67 | 1.16 | 0.15
TRT*NYHA III | - | - | - | 1.29 | 1.20 | 0.29
TRT*NYHA IV | - | - | - | - | - | -
TRT*ISCH | - | - | - | - | - | -

Abbreviations for Appendix Table A9: EF = ejection fraction; ISCH = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; NYHA = New York Heart Association; SE = standard error; TRT = treatment

Appendix Table A10 Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from Weibull regression models fit to the MADIT-II trial

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.47 | 0.14 | 0.00 | −0.28 | 0.33 | 0.39
AGE [65,75) | 0.63 | 0.16 | 0.00 | 0.77 | 0.23 | 0.00
AGE ≥ 75 | 1.12 | 0.18 | 0.00 | 1.22 | 0.27 | 0.00
EF > 30% | 0.75 | 1.01 | 0.46 | 0.74 | 1.02 | 0.47
NYHA II | 0.02 | 0.19 | 0.91 | 0.05 | 0.26 | 0.85
NYHA III | 0.74 | 0.17 | 0.00 | 0.85 | 0.24 | 0.00
NYHA IV | 1.02 | 0.26 | 0.00 | 0.50 | 0.45 | 0.26
ISCH | - | - | - | - | - | -
TRT*AGE [65,75) | - | - | - | −0.29 | 0.33 | 0.37
TRT*AGE ≥ 75 | - | - | - | −0.20 | 0.37 | 0.59
TRT*EF > 30% | - | - | -
TRT*NYHA II | - | - | - | −0.06 | 0.37 | 0.88
TRT*NYHA III | - | - | - | −0.22 | 0.35 | 0.54
TRT*NYHA IV | - | - | - | 0.91 | 0.56 | 0.10
TRT*ISCH | - | - | - | - | - | -

Abbreviations for Appendix Table A10: EF = ejection fraction; ISCH = ischemic; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; NYHA = New York Heart Association; SE = standard error; TRT = treatment

Appendix Table A11 Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from Weibull regression models fit to the MUSTT trial

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.97 | 0.24 | 0.00 | 0.05 | 0.50 | 0.93
AGE [65,75) | 0.07 | 0.22 | 0.75 | 0.17 | 0.25 | 0.49
AGE ≥ 75 | −0.10 | 0.28 | 0.71 | −0.07 | 0.30 | 0.83
EF > 30% | −0.57 | 0.24 | 0.02 | −0.54 | 0.26 | 0.04
NYHA II | 0.52 | 0.26 | 0.04 | 0.79 | 0.30 | 0.01
NYHA III | 1.07 | 0.26 | 0.00 | 1.32 | 0.30 | 0.00
NYHA IV | - | - | - | - | - | -
ISCH | - | - | - | - | - | -
TRT*AGE [65,75) | - | - | - | −0.35 | 0.53 | 0.51
TRT*AGE ≥ 75 | - | - | - | 0.06 | 0.74 | 0.94
TRT*EF > 30% | - | - | - | −0.24 | 0.62 | 0.69
TRT*NYHA II | - | - | - | −1.21 | 0.62 | 0.05
TRT*NYHA III | - | - | - | −1.07 | 0.60 | 0.08
TRT*NYHA IV | - | - | - | - | - | -
TRT*ISCH | - | - | - | - | - | -

Abbreviations for Appendix Table A11: EF = ejection fraction; ISCH = ischemic; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SE = standard error; TRT = treatment

Appendix Table A12 Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from Weibull regression models fit to the SCD-HeFT trial

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.30 | 0.10 | 0.00 | −0.78 | 0.21 | 0.00
AGE [65,75) | 0.52 | 0.11 | 0.00 | 0.39 | 0.14 | 0.01
AGE ≥ 75 | 0.52 | 0.16 | 0.00 | 0.59 | 0.21 | 0.00
EF > 30% | −0.58 | 0.11 | 0.00 | −0.69 | 0.14 | 0.00
NYHA II | - | - | - | - | - | -
NYHA III | 0.72 | 0.10 | 0.00 | 0.41 | 0.13 | 0.00
NYHA IV | - | - | - | - | - | -
ISCH | 0.58 | 0.10 | 0.00 | 0.59 | 0.14 | 0.00
TRT*AGE [65,75) | - | - | - | 0.28 | 0.22 | 0.19
TRT*AGE ≥ 75 | - | - | - | −0.22 | 0.32 | 0.49
TRT*EF > 30% | - | - | - | 0.29 | 0.22 | 0.18
TRT*NYHA II | - | - | - | - | - | -
TRT*NYHA III | - | - | - | 0.71 | 0.20 | 0.00
TRT*NYHA IV | - | - | - | - | - | -
TRT*ISCH | - | - | - | −0.01 | 0.21 | 0.95

Abbreviations for Appendix Table A12: EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; SE = standard error; TRT = treatment

Before we move on to the next phase of the analysis we take a quick detour to explain in more detail the results we presented in Appendix Tables A5–A12. Because all these tables have similar format, we do not discuss them individually, but focus on the results in Appendix Table A5. The left side of the table shows results that only include main effects, while the right side of the table shows results that include main effects and interactions between treatment and prognostic variables. The results include estimates of the model parameters, standard errors and p-values. For example, for the model that utilizes only main effects, we estimate that the hazard of death from all causes for a patient in the ICD group is exp(−0.43) = 0.65 times the hazard of death for a patient in the control group.

Appendix Figure A2 summarizes the analysis of the individual trials displaying estimates, along with the respective 95 percent confidence intervals, of the log-hazard of treatment effect for each trial. The differences between estimates from models that do not adjust for covariates from those that do are, in general, relatively small. Without covariate adjustment there is evidence of treatment effect on overall survival in five trials (AVID, MADIT-I, MADIT-II, MUSTT and SCD-HeFT) as shown in the figure with the 95 percent CI excluding the null value (zero). When considering covariate adjustment, we also find a (borderline) treatment effect in the DEFINITE trial. We note, however, that the estimates vary from trial to trial. Moreover, the precisions for these estimates vary, with more precision attained in the largest trial (SCD-HeFT) with the narrowest 95 percent CI.

Appendix Figure A2 Log-hazard of treatment effect from Weibull Regression model fit to individual trials with and without covariate adjustment. Vertical segments show the limits of the 95% confidence intervals. They are displayed in blocks of segments with different colors to differentiate results by trial. Within each block, the full line displays results without covariate adjustment; the dotted line displays results utilizing covariate adjustment (note AGE and EF are categorized)

Key points: The analysis of the individual trials shows that, out of eight trials, five showed evidence of treatment effect, but there is also a lot of variation in the estimates of ICD effect across trials. Within any trial, the results are fairly robust to different model formulations. Moreover, generally, there is no evidence of significant treatment-covariate interactions in the prognostic subgroups.

### Analysis of Data Combining All Trials

Under all model formulations considered here, there is evidence of treatment effect on overall survival (Appendix Tables A13–A17, with results presented in similar format to those discussed in the previous section).

Appendix Table A13 Combined analysis without covariate adjustment (except for trial effects)

| Weibull Regression Model | | | Bayesian Weibull Regression Model
| Estimate | 95% CI Lower | 95% CI Upper | Estimate | 95% CI Lower | 95% CI Upper
Without adjustment for trial effect | −0.38 | −0.48 | −0.27 | −0.36 | −0.46 | −0.26
Fixed trial effects | −0.36 | −0.47 | −0.26 | −0.35 | −0.45 | −0.23
Random trial effects | −0.38 | −0.48 | −0.28 | −0.36 | −0.46 | −0.25
Trial-specific baseline hazard | −0.36 | −0.47 | −0.26 | −0.37 | −0.48 | −0.25

Abbreviation for Appendix Table A13: CI = confidence interval

Appendix Table A14 Combined analysis. Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from the Weibull regression models fit to all trials without adjustment for trial effects

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.38 | 0.06 | 0.00 | −0.42 | 0.19 | 0.03
AGE [65,75) | 0.48 | 0.06 | 0.00 | 0.43 | 0.08 | 0.00
AGE ≥ 75 | 0.67 | 0.08 | 0.00 | 0.62 | 0.11 | 0.00
EF > 30% | −0.35 | 0.06 | 0.00 | −0.43 | 0.08 | 0.00
NYHA II | 0.26 | 0.07 | 0.00 | 0.33 | 0.10 | 0.00
NYHA III | 0.87 | 0.08 | 0.00 | 0.85 | 0.10 | 0.00
NYHA IV | 0.60 | 0.18 | 0.00 | 0.24 | 0.28 | 0.38
ISCH | 0.52 | 0.07 | 0.00 | 0.55 | 0.10 | 0.00
TRT*AGE [65,75) | - | - | - | 0.14 | 0.12 | 0.26
TRT*AGE ≥ 75 | - | - | - | 0.12 | 0.16 | 0.44
TRT*EF > 30% | - | - | - | 0.20 | 0.13 | 0.13
TRT*NYHA II | - | - | - | −0.16 | 0.15 | 0.28
TRT*NYHA III | - | - | - | 0.05 | 0.15 | 0.74
TRT*NYHA IV | - | - | - | 0.67 | 0.36 | 0.07
TRT*ISCH | - | - | - | −0.07 | 0.15 | 0.65

Abbreviations for Appendix Table A14: EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SE = standard error; TRT = treatment

Appendix Table A15 Combined analysis. Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from the Weibull regression models fit to all trials with fixed trial effects

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.35 | 0.06 | 0.00 | −0.44 | 0.19 | 0.02
AGE [65,75) | 0.49 | 0.06 | 0.00 | 0.44 | 0.08 | 0.00
AGE ≥ 75 | 0.68 | 0.08 | 0.00 | 0.62 | 0.11 | 0.00
EF > 30% | −0.49 | 0.07 | 0.00 | −0.57 | 0.09 | 0.00
NYHA II | 0.33 | 0.08 | 0.00 | 0.40 | 0.10 | 0.00
NYHA III | 0.99 | 0.08 | 0.00 | 0.96 | 0.10 | 0.00
NYHA IV | 0.85 | 0.18 | 0.00 | 0.50 | 0.28 | 0.08
ISCH | 0.45 | 0.09 | 0.00 | 0.46 | 0.11 | 0.00
CABG-PATCH | −0.63 | 0.11 | 0.00 | −0.63 | 0.11 | 0.00
CASH | 0.11 | 0.13 | 0.39 | 0.12 | 0.13 | 0.36
DEFINITE | −0.63 | 0.16 | 0.00 | −0.63 | 0.17 | 0.00
MADIT-I | −0.21 | 0.15 | 0.17 | −0.22 | 0.16 | 0.16
MADIT-II | −0.73 | 0.10 | 0.00 | −0.73 | 0.11 | 0.00
MUSTT | −0.37 | 0.12 | 0.00 | −0.37 | 0.12 | 0.00
SCD-HeFT | −0.60 | 0.10 | 0.00 | −0.60 | 0.10 | 0.00
TRT*AGE [65,75) | - | - | - | 0.13 | 0.12 | 0.29
TRT*AGE ≥ 75 | - | - | - | 0.15 | 0.16 | 0.34
TRT*EF > 30% | - | - | - | 0.19 | 0.13 | 0.14
TRT*NYHA II | - | - | - | −0.15 | 0.15 | 0.32
TRT*NYHA III | - | - | - | 0.08 | 0.15 | 0.60
TRT*NYHA IV | - | - | - | 0.66 | 0.36 | 0.07
TRT*ISCH | - | - | - | −0.02 | 0.15 | 0.88

Abbreviations for Appendix Table A15: CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ISCH = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; SE = standard error; TRT = treatment

Appendix Table A16 Combined analysis. Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from the Weibull regression models fit to all trials with random trial effects

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.38 | 0.06 | 0.00 | −0.43 | 0.19 | 0.03
AGE [65,75) | 0.47 | 0.06 | 0.00 | 0.41 | 0.08 | 0.00
AGE ≥ 75 | 0.66 | 0.08 | 0.00 | 0.60 | 0.11 | 0.00
EF > 30% | −0.35 | 0.06 | 0.00 | −0.42 | 0.08 | 0.00
NYHA II | 0.40 | 0.08 | 0.00 | 0.47 | 0.10 | 0.00
NYHA III | 1.01 | 0.08 | 0.00 | 0.99 | 0.10 | 0.00
NYHA IV | 0.62 | 0.18 | 0.00 | 0.26 | 0.28 | 0.35
ISCH | 0.48 | 0.07 | 0.00 | 0.51 | 0.10 | 0.00
TRT*AGE [65,75) | - | - | - | 0.15 | 0.12 | 0.23
TRT*AGE ≥ 75 | - | - | - | 0.13 | 0.16 | 0.42
TRT*EF > 30% | - | - | - | 0.18 | 0.13 | 0.16
TRT*NYHA II | - | - | - | −0.16 | 0.15 | 0.30
TRT*NYHA III | - | - | - | 0.06 | 0.15 | 0.69
TRT*NYHA IV | - | - | - | 0.68 | 0.36 | 0.06
TRT*ISCH | - | - | - | −0.06 | 0.15 | 0.67

Abbreviations for Appendix Table A16: EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SE = standard error; TRT = treatment

Appendix Table A17 Combined analysis. Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Weibull regression model. Estimates from the Weibull regression models fit to all trials with trial-specific baseline hazard functions

Parameter | Model with Main Effects Only | | | Model with Interactions
Parameter | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.35 | 0.06 | 0.00 | −0.46 | 0.19 | 0.02
AGE [65,75) | 0.50 | 0.06 | 0.00 | 0.44 | 0.08 | 0.00
AGE ≥ 75 | 0.69 | 0.08 | 0.00 | 0.63 | 0.11 | 0.00
EF > 30% | −0.49 | 0.07 | 0.00 | −0.58 | 0.09 | 0.00
NYHA II | 0.32 | 0.08 | 0.00 | 0.38 | 0.10 | 0.00
NYHA III | 0.99 | 0.08 | 0.00 | 0.94 | 0.10 | 0.00
NYHA IV | 0.83 | 0.18 | 0.00 | 0.47 | 0.28 | 0.09
ISCH | 0.46 | 0.09 | 0.00 | 0.47 | 0.11 | 0.00
TRT*AGE [65,75) | - | - | - | 0.13 | 0.12 | 0.28
TRT*AGE ≥ 75 | - | - | - | 0.15 | 0.16 | 0.34
TRT*EF > 30% | - | - | - | 0.20 | 0.13 | 0.12
TRT*NYHA II | - | - | - | −0.14 | 0.15 | 0.34
TRT*NYHA III | - | - | - | 0.10 | 0.15 | 0.53
TRT*NYHA IV | - | - | - | 0.68 | 0.36 | 0.06
TRT*ISCH | - | - | - | −0.01 | 0.15 | 0.93

Abbreviations for Appendix Table A17: EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SE = standard error; TRT = treatment

Moreover, estimates from Bayesian models (Appendix Tables A18–A21) with priors as described before, are generally similar to those obtained under the frequentist Weibull regression models (compare results under Appendix Tables A18–A21 with those from Appendix Tables A13–A17). We note that in Appendix Tables A18–A21 we present the posterior mean, posterior standard deviation and 95 percent posterior credible intervals. Let us take the results under Appendix Table A18 for the model that only includes main effects for an example. We estimate that the hazard of death in the ICD is approximately exp(−0.38) = 0.68 times the hazard of death in the control group. Moreover, we estimate that with 95 percent posterior probability the hazard ratio lies between 0.61 and 0.76.

Appendix Table A18 Combined analysis. Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Bayesian Weibull regression model. Estimates from the Bayesian Weibull regression models fit to all trials without adjustment for trial effects

Parameter | Model with Main Effects Only | | | | Model with Interactions
Parameter | Estimate | SD | 95% Credible Interval | | Estimate | SD | 95% Credible Interval
TRT | −0.38 | 0.06 | −0.50 | −0.27 | −0.35 | 0.20 | −0.80 | 0.00
AGE [65,75) | 0.47 | 0.06 | 0.36 | 0.58 | 0.42 | 0.07 | 0.29 | 0.57
AGE ≥ 75 | 0.66 | 0.08 | 0.50 | 0.81 | 0.61 | 0.10 | 0.39 | 0.80
EF > 30% | −0.35 | 0.06 | −0.47 | −0.23 | −0.43 | 0.09 | −0.61 | −0.26
NYHA II | 0.23 | 0.07 | 0.10 | 0.39 | 0.33 | 0.09 | 0.13 | 0.50
NYHA III | 0.85 | 0.07 | 0.70 | 0.98 | 0.85 | 0.10 | 0.64 | 1.04
NYHA IV | 0.56 | 0.17 | 0.24 | 0.89 | 0.19 | 0.24 | −0.32 | 0.66
ISCH | 0.51 | 0.07 | 0.36 | 0.65 | 0.55 | 0.09 | 0.35 | 0.72
TRT*AGE [65,75) | - | - | - | - | 0.13 | 0.12 | −0.12 | 0.35
TRT*AGE ≥ 75 | - | - | - | - | 0.12 | 0.15 | −0.16 | 0.40
TRT*EF > 30% | - | - | - | - | 0.16 | 0.13 | −0.11 | 0.40
TRT*NYHA II | - | - | - | - | −0.21 | 0.15 | −0.46 | 0.09
TRT*NYHA III | - | - | - | - | 0.00 | 0.15 | −0.28 | 0.32
TRT*NYHA IV | - | - | - | - | 0.66 | 0.33 | 0.00 | 1.28
TRT*ISCH | - | - | - | - | −0.09 | 0.15 | −0.40 | 0.17

Abbreviations for Appendix Table A18: EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SD = standard deviation; TRT = treatment

Appendix Table A19 Combined analysis. Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Bayesian Weibull regression model. Estimates from the Bayesian Weibull regression models fit to all trials with fixed trial effects

Parameter | Model with Main Effects Only | | | | Model with Interactions
Parameter | Estimate | SD | 95% Credible Interval | | Estimate | SD | 95% Credible Interval
TRT | −0.35 | 0.05 | −0.45 | −0.25 | −0.43 | 0.19 | −0.82 | −0.08
AGE [65,75) | 0.49 | 0.06 | 0.37 | 0.61 | 0.42 | 0.07 | 0.28 | 0.56
AGE ≥ 75 | 0.67 | 0.08 | 0.51 | 0.83 | 0.60 | 0.10 | 0.38 | 0.78
EF > 30% | −0.49 | 0.07 | −0.62 | −0.36 | −0.57 | 0.09 | −0.75 | −0.38
NYHA II | 0.32 | 0.09 | 0.16 | 0.50 | 0.39 | 0.12 | 0.16 | 0.60
NYHA III | 0.98 | 0.09 | 0.81 | 1.16 | 0.96 | 0.11 | 0.72 | 1.17
NYHA IV | 0.82 | 0.17 | 0.50 | 1.16 | 0.51 | 0.28 | −0.08 | 1.00
ISCH | 0.43 | 0.09 | 0.24 | 0.64 | 0.45 | 0.10 | 0.26 | 0.64
AVID | 0.19 | 0.53 | −0.69 | 0.96 | 0.14 | 0.23 | −0.29 | 0.51
CABG-PATCH | −0.43 | 0.52 | −1.32 | 0.29 | −0.49 | 0.23 | −0.91 | −0.12
CASH | 0.30 | 0.52 | −0.62 | 1.07 | 0.25 | 0.25 | −0.27 | 0.69
DEFINITE | −0.46 | 0.55 | −1.44 | 0.38 | −0.51 | 0.26 | −1.01 | −0.02
MADIT-I | −0.02 | 0.53 | −0.95 | 0.77 | −0.07 | 0.25 | −0.57 | 0.36
MADIT-II | −0.52 | 0.53 | −1.40 | 0.26 | −0.57 | 0.23 | −1.00 | −0.20
MUSTT | −0.18 | 0.53 | −1.07 | 0.61 | −0.22 | 0.25 | −0.70 | 0.19
SCD-HeFT | −0.41 | 0.52 | −1.26 | 0.38 | −0.46 | 0.24 | −0.92 | −0.08
TRT*AGE [65,75) | - | - | - | - | 0.15 | 0.11 | −0.06 | 0.37
TRT*AGE ≥ 75 | - | - | - | - | 0.15 | 0.15 | −0.13 | 0.45
TRT*EF > 30% | - | - | - | - | 0.20 | 0.12 | −0.04 | 0.42
TRT*NYHA II | - | - | - | - | −0.16 | 0.16 | −0.48 | 0.18
TRT*NYHA III | - | - | - | - | 0.06 | 0.17 | −0.25 | 0.43
TRT*NYHA IV | - | - | - | - | 0.60 | 0.35 | −0.05 | 1.29
TRT*ISCH | - | - | - | - | −0.04 | 0.16 | −0.32 | 0.31

Abbreviations for Appendix Table A19: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ISCH = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; SD = standard deviation; TRT = treatment

Appendix Table A20 Combined analysis. Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Bayesian Weibull regression model. Estimates from the Bayesian Weibull regression models fit to all trials with random trial effects

Parameter | Model with Main Effects Only | | | | Model with Interactions
Parameter | Estimate | SD | 95% Credible Interval | | Estimate | SD | 95% Credible Interval
TRT | −0.36 | 0.05 | −0.47 | −0.26 | −0.58 | 0.18 | −0.92 | −0.21
AGE [65,75) | 0.49 | 0.06 | 0.38 | 0.61 | 0.43 | 0.07 | 0.31 | 0.57
AGE ≥ 75 | 0.68 | 0.08 | 0.53 | 0.84 | 0.59 | 0.11 | 0.36 | 0.80
EF > 30% | −0.49 | 0.07 | −0.62 | −0.36 | −0.58 | 0.08 | −0.74 | −0.42
NYHA II | 0.31 | 0.08 | 0.15 | 0.44 | 0.34 | 0.09 | 0.19 | 0.51
NYHA III | 0.96 | 0.08 | 0.80 | 1.12 | 0.91 | 0.09 | 0.73 | 1.08
NYHA IV | 0.78 | 0.18 | 0.43 | 1.12 | 0.45 | 0.25 | −0.07 | 0.92
ISCH | 0.44 | 0.09 | 0.26 | 0.64 | 0.38 | 0.10 | 0.18 | 0.56
TRT*AGE [65,75) | - | - | - | - | 0.16 | 0.11 | −0.07 | 0.37
TRT*AGE ≥ 75 | - | - | - | - | 0.17 | 0.16 | −0.14 | 0.48
TRT*EF > 30% | - | - | - | - | 0.19 | 0.14 | −0.07 | 0.44
TRT*NYHA II | - | - | - | - | −0.09 | 0.14 | −0.40 | 0.16
TRT*NYHA III | - | - | - | - | 0.13 | 0.13 | −0.12 | 0.38
TRT*NYHA IV | - | - | - | - | 0.64 | 0.33 | 0.01 | 1.30
TRT*ISCH | - | - | - | - | 0.07 | 0.16 | −0.25 | 0.33

Abbreviations for Appendix Table A20: EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SD = standard deviation; TRT = treatment

Appendix Table A21 Combined analysis. Comparison of overall survival by treatment group adjusted by baseline prognostic variables using the Bayesian Weibull regression model. Estimates from the Bayesian Weibull regression models fit to all trials with trial-specific baseline hazard functions

Parameter | Model with Main Effects Only | | | | Model with Interactions
Parameter | Estimate | SD | 95% Credible Interval | | Estimate | SD | 95% Credible Interval
TRT | −0.35 | 0.06 | −0.45 | −0.24 | −0.50 | 0.18 | −0.85 | −0.19
AGE [65,75) | 0.49 | 0.06 | 0.37 | 0.61 | 0.42 | 0.08 | 0.27 | 0.58
AGE ≥ 75 | 0.68 | 0.08 | 0.53 | 0.84 | 0.60 | 0.10 | 0.41 | 0.79
EF > 30% | −0.50 | 0.07 | −0.65 | −0.37 | −0.58 | 0.09 | −0.76 | −0.42
NYHA II | 0.29 | 0.08 | 0.12 | 0.44 | 0.36 | 0.09 | 0.19 | 0.55
NYHA III | 0.96 | 0.09 | 0.78 | 1.11 | 0.92 | 0.09 | 0.74 | 1.09
NYHA IV | 0.77 | 0.19 | 0.38 | 1.13 | 0.46 | 0.27 | −0.12 | 0.94
ISCH | 0.42 | 0.09 | 0.23 | 0.59 | 0.43 | 0.09 | 0.25 | 0.62
TRT*AGE [65,75) | - | - | - | - | 0.16 | 0.12 | −0.08 | 0.37
TRT*AGE ≥ 75 | - | - | - | - | 0.17 | 0.15 | −0.12 | 0.48
TRT*EF > 30% | - | - | - | - | 0.20 | 0.12 | −0.05 | 0.44
TRT*NYHA II | - | - | - | - | −0.13 | 0.14 | −0.40 | 0.15
TRT*NYHA III | - | - | - | - | 0.11 | 0.13 | −0.13 | 0.38
TRT*NYHA IV | - | - | - | - | 0.63 | 0.33 | −0.01 | 1.29
TRT*ISCH | - | - | - | - | 0.01 | 0.14 | −0.30 | 0.26

Abbreviations for Appendix Table A21: EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SD = standard deviation; TRT = treatment

Appendix Figure A3 summarizes results displaying estimates, along with the corresponding 95 percent confidence/credible intervals, of the log-hazard of treatment effect across different models. The results show evidence of treatment effect on overall survival and are very similar across all models considered here, that is, with or without covariate adjustment, and across different specifications for how trial data are combined, with Weibull regression models using frequentist or Bayesian approaches to estimation. Moreover, the estimates have lower uncertainty as compared to those from the individual trials (compare Appendix Figure A3 with Appendix Figure A2).

Appendix Figure A3 Log-hazard of treatment effect from Weibull Regression models that combine data across trials with or without adjustment for covariates. Estimates obtained using Weibull Regression Models are shown with filled symbols, specifically, filled dots for frequentist estimates and filled squares for Bayesian estimates. Vertical segments give the limits of the 95% confidence/credible intervals. They are displayed in blocks of segments with different colors to differentiate results by the modeling approaches utilized to combine trials. Within each block, the full line displays results without covariate adjustment; the following set utilizes covariate adjustment

The models that we discussed so far rely on strong assumptions as to how we accommodate trial differences. In one extreme end, we combine data assuming that trials are similar. Next, we relax this assumption and assume that trial differences are accommodated with fixed and random trial effects or allowing for trial-specific baseline hazard functions. However, we have allowed the effect of the prognostic variables, and the interactions to be similar across all trials. Next, we discuss results from a Bayesian hierarchical model that will relax this assumption. We note that an equivalent model, without priors in the population parameters, could not be estimated using classical frequentist approaches.

Appendix Table A22 shows estimates under the full Bayesian hierarchical model that accounts for trial variation in the baseline-hazard, main effects and interaction effects. To summarize the results we present the population estimates, as well as, the trial-specific estimates. From Appendix Table A22 we estimate, under the model that only includes main effects, that the hazard of death in the ICD is approximately exp(−0.43) = 0.65 times the hazard of death in the control group. Moreover, we estimate that with 95 percent posterior probability the hazard ratio lies between 0.40 and 1.03. This model also allows us to obtain the trial-specific effects. We find differential effect of ICD across trials. In particular, we find no treatment effect in the CABG-PATCH and CASH (95 percent posterior credible intervals include the null value) trials. There is no evidence of interactions between treatment and any of the prognostic variables.

Appendix Table A22 Combined analysis. Estimates from the Bayesian Hierarchical Weibull Regression Model with categorical (AGE and EF)

Effect | Source | Trial | Model with Main Effects Only | | | | Model with Interactions
Effect | Source | Trial | Estimate | SD | 95% Credible Interval | | Estimate | SD | 95% Credible Interval
TRT | Population | - | −0.43 | 0.23 | −0.88 | 0.02 | −0.50 | 0.30 | −1.07 | 0.12
AGE [65,75) | Population | - | 0.45 | 0.21 | 0.02 | 0.85 | 0.41 | 0.21 | −0.01 | 0.83
AGE ≥ 75 | Population | - | 0.60 | 0.26 | 0.09 | 1.11 | 0.62 | 0.27 | 0.07 | 1.13
EF > 30% | Population | - | −0.41 | 0.26 | −0.89 | 0.14 | −0.41 | 0.27 | −0.94 | 0.17
NYHA II | Population | - | 0.27 | 0.22 | −0.20 | 0.68 | 0.36 | 0.24 | −0.11 | 0.83
NYHA III | Population | - | 0.92 | 0.24 | 0.44 | 1.37 | 1.01 | 0.24 | 0.55 | 1.45
NYHA IV | Population | - | 0.44 | 0.61 | −0.85 | 1.61 | 0.33 | 0.62 | −0.92 | 1.55
ISCH | Population | - | −0.07 | 0.34 | −0.77 | 0.58 | −0.01 | 0.34 | −0.69 | 0.61
TRT*AGE [65,75) | Population | - | | | | | 0.08 | 0.26 | −0.48 | 0.58
TRT*AGE ≥ 75 | Population | - | | | | | −0.06 | 0.32 | −0.72 | 0.55
TRT*EF > 30% | Population | - | | | | | 0.02 | 0.33 | −0.63 | 0.64
TRT*NYHA II | Population | - | | | | | −0.09 | 0.30 | −0.65 | 0.47
TRT*NYHA III | Population | - | | | | | −0.05 | 0.30 | −0.64 | 0.54
TRT*NYHA IV | Population | - | | | | | 0.31 | 0.65 | −0.99 | 1.65
TRT*ISCH | Population | - | | | | | 0.04 | 0.33 | −0.63 | 0.68
TRT | Trial-specific | AVID | −0.44 | 0.14 | −0.70 | −0.16 | −0.40 | 0.40 | −1.05 | 0.64
TRT | Trial-specific | CABG-PATCH | 0.04 | 0.14 | −0.23 | 0.32 | −0.51 | 0.42 | −1.27 | 0.39
TRT | Trial-specific | CASH | −0.21 | 0.20 | −0.60 | 0.15 | −0.95 | 0.42 | −1.73 | −0.10
TRT | Trial-specific | DEFINITE | −0.54 | 0.23 | −1.03 | −0.11 | −0.45 | 0.38 | −1.36 | 0.25
TRT | Trial-specific | MADIT-I | −0.79 | 0.27 | −1.34 | −0.30 | −0.77 | 0.52 | −1.82 | 0.35
TRT | Trial-specific | MADIT-II | −0.47 | 0.15 | −0.75 | −0.20 | −0.34 | 0.49 | −1.29 | 0.51
TRT | Trial-specific | MUSTT | −0.89 | 0.22 | −1.31 | −0.49 | −0.47 | 0.52 | −1.57 | 0.52
TRT | Trial-specific | SCD-HeFT | −0.31 | 0.09 | −0.49 | −0.14 | −0.31 | 0.29 | −0.88 | 0.22
AGE [65,75) | Trial-specific | AVID | 0.32 | 0.15 | 0.03 | 0.62 | 0.36 | 0.20 | 0.03 | 0.80
AGE [65,75) | Trial-specific | CABG-PATCH | 0.60 | 0.15 | 0.30 | 0.88 | 0.49 | 0.18 | 0.15 | 0.82
AGE [65,75) | Trial-specific | CASH | 0.62 | 0.22 | 0.17 | 1.03 | 0.51 | 0.23 | 0.03 | 0.96
AGE [65,75) | Trial-specific | DEFINITE | 0.39 | 0.24 | −0.07 | 0.89 | 0.36 | 0.26 | −0.15 | 0.86
AGE [65,75) | Trial-specific | MADIT-I | 0.55 | 0.26 | 0.06 | 1.07 | 0.52 | 0.29 | −0.09 | 1.06
AGE [65,75) | Trial-specific | MADIT-II | 0.61 | 0.15 | 0.34 | 0.94 | 0.68 | 0.22 | 0.25 | 1.14
AGE [65,75) | Trial-specific | MUSTT | 0.15 | 0.19 | −0.24 | 0.53 | 0.20 | 0.21 | −0.24 | 0.60
AGE [65,75) | Trial-specific | SCD-HeFT | 0.51 | 0.10 | 0.31 | 0.70 | 0.40 | 0.14 | 0.13 | 0.66
AGE ≥ 75 | Trial-specific | AVID | 0.64 | 0.17 | 0.30 | 0.97 | 0.55 | 0.23 | 0.12 | 1.02
AGE ≥ 75 | Trial-specific | CABG-PATCH | 0.66 | 0.20 | 0.30 | 1.04 | 0.43 | 0.27 | −0.08 | 0.94
AGE ≥ 75 | Trial-specific | CASH | 0.78 | 0.39 | −0.06 | 1.50 | 0.79 | 0.45 | −0.12 | 1.62
AGE ≥ 75 | Trial-specific | DEFINITE | 0.99 | 0.31 | 0.43 | 1.59 | 1.21 | 0.43 | 0.35 | 2.06
AGE ≥ 75 | Trial-specific | MADIT-I | 0.63 | 0.37 | −0.10 | 1.33 | 0.64 | 0.39 | −0.15 | 1.37
AGE ≥ 75 | Trial-specific | MADIT-II | 1.07 | 0.18 | 0.72 | 1.43 | 1.08 | 0.26 | 0.58 | 1.59
AGE ≥ 75 | Trial-specific | MUSTT | 0.04 | 0.25 | −0.46 | 0.49 | 0.03 | 0.25 | −0.50 | 0.52
AGE ≥ 75 | Trial-specific | SCD-HeFT | 0.52 | 0.15 | 0.24 | 0.79 | 0.59 | 0.20 | 0.19 | 0.97
EF > 30% | Trial-specific | AVID | −0.53 | 0.15 | −0.82 | −0.26 | −0.67 | 0.19 | −1.03 | −0.31
EF > 30% | Trial-specific | CABG-PATCH | −0.26 | 0.17 | −0.61 | 0.07 | −0.18 | 0.21 | −0.60 | 0.23
EF > 30% | Trial-specific | CASH | −0.27 | 0.22 | −0.67 | 0.16 | −0.36 | 0.23 | −0.81 | 0.05
EF > 30% | Trial-specific | DEFINITE | −0.31 | 0.45 | −1.24 | 0.52 | −0.34 | 0.47 | −1.27 | 0.56
EF > 30% | Trial-specific | MADIT-I | −0.63 | 0.35 | −1.39 | 0.05 | −0.58 | 0.40 | −1.40 | 0.12
EF > 30% | Trial-specific | MADIT-II | −0.19 | 0.60 | −1.36 | 1.07 | −0.23 | 0.65 | −1.42 | 1.10
EF > 30% | Trial-specific | MUSTT | −0.56 | 0.22 | −0.98 | −0.12 | −0.52 | 0.23 | −1.00 | −0.07
EF > 30% | Trial-specific | SCD-HeFT | −0.59 | 0.11 | −0.80 | −0.38 | −0.69 | 0.14 | −1.00 | −0.42
NYHA II | Trial-specific | AVID | 0.43 | 0.16 | 0.13 | 0.75 | 0.51 | 0.18 | 0.15 | 0.88
NYHA II | Trial-specific | CABG-PATCH | 0.49 | 0.19 | 0.10 | 0.84 | 0.34 | 0.24 | −0.13 | 0.78
NYHA II | Trial-specific | CASH | 0.55 | 0.23 | 0.09 | 1.00 | 0.62 | 0.27 | 0.10 | 1.14
NYHA II | Trial-specific | DEFINITE | −0.10 | 0.26 | −0.57 | 0.41 | −0.07 | 0.29 | −0.62 | 0.46
NYHA II | Trial-specific | MADIT-I | 0.46 | 0.29 | −0.11 | 1.04 | 0.37 | 0.29 | −0.23 | 0.94
NYHA II | Trial-specific | MADIT-II | 0.05 | 0.18 | −0.31 | 0.39 | 0.14 | 0.24 | −0.30 | 0.58
NYHA II | Trial-specific | MUSTT | 0.44 | 0.24 | −0.04 | 0.91 | 0.63 | 0.25 | 0.17 | 1.17
NYHA II | Trial-specific | SCD-HeFT | 0.04 | 0.34 | −0.61 | 0.71 | 0.39 | 0.37 | −0.34 | 1.19
NYHA III | Trial-specific | AVID | 0.94 | 0.19 | 0.57 | 1.28 | 0.98 | 0.21 | 0.58 | 1.38
NYHA III | Trial-specific | CABG-PATCH | 0.90 | 0.18 | 0.55 | 1.23 | 0.88 | 0.22 | 0.44 | 1.25
NYHA III | Trial-specific | CASH | 1.48 | 0.29 | 0.92 | 2.06 | 1.32 | 0.31 | 0.70 | 1.92
NYHA III | Trial-specific | DEFINITE | 0.70 | 0.28 | 0.13 | 1.21 | 0.98 | 0.31 | 0.42 | 1.63
NYHA III | Trial-specific | MADIT-I | 1.31 | 0.33 | 0.69 | 1.97 | 1.30 | 0.32 | 0.66 | 1.98
NYHA III | Trial-specific | MADIT-II | 0.75 | 0.17 | 0.39 | 1.06 | 0.90 | 0.20 | 0.53 | 1.29
NYHA III | Trial-specific | MUSTT | 0.98 | 0.23 | 0.52 | 1.47 | 1.17 | 0.25 | 0.73 | 1.67
NYHA III | Trial-specific | SCD-HeFT | 0.76 | 0.34 | 0.13 | 1.41 | 0.83 | 0.38 | 0.06 | 1.63
NYHA IV | Trial-specific | AVID | 0.38 | 1.33 | −2.48 | 3.08 | 0.35 | 1.25 | −2.32 | 2.72
NYHA IV | Trial-specific | CABG-PATCH | 0.45 | 0.28 | −0.12 | 0.96 | 0.42 | 0.35 | −0.31 | 1.07
NYHA IV | Trial-specific | CASH | 0.38 | 1.34 | −2.35 | 3.02 | 0.29 | 1.32 | −2.21 | 2.70
NYHA IV | Trial-specific | DEFINITE | 0.41 | 1.36 | −2.33 | 2.97 | 0.31 | 1.44 | −2.57 | 3.07
NYHA IV | Trial-specific | MADIT-I | 0.45 | 1.36 | −2.55 | 3.26 | 0.37 | 1.32 | −2.39 | 2.75
NYHA IV | Trial-specific | MADIT-II | 0.97 | 0.26 | 0.43 | 1.44 | 0.54 | 0.40 | −0.21 | 1.33
NYHA IV | Trial-specific | MUSTT | 0.44 | 1.37 | −2.45 | 3.01 | 0.36 | 1.34 | −2.32 | 2.98
NYHA IV | Trial-specific | SCD-HeFT | 0.49 | 1.35 | −2.41 | 3.11 | 0.33 | 1.29 | −2.34 | 2.79
ISCH | Trial-specific | AVID | 0.28 | 0.21 | −0.11 | 0.66 | 0.33 | 0.19 | −0.04 | 0.70
ISCH | Trial-specific | CABG-PATCH | −1.01 | 0.39 | −1.75 | −0.15 | −0.96 | 0.38 | −1.60 | −0.36
ISCH | Trial-specific | CASH | −0.20 | 0.29 | −0.70 | 0.40 | −0.27 | 0.32 | −0.86 | 0.36
ISCH | Trial-specific | DEFINITE | −0.06 | 0.98 | −2.08 | 1.93 | −0.06 | 0.88 | −1.88 | 1.63
ISCH | Trial-specific | MADIT-I | −0.01 | 0.69 | −1.35 | 1.65 | −0.10 | 0.57 | −1.10 | 1.11
ISCH | Trial-specific | MADIT-II | −0.11 | 0.32 | −0.66 | 0.54 | 0.11 | 0.43 | −0.79 | 0.99
ISCH | Trial-specific | MUSTT | 0.00 | 0.56 | −1.05 | 1.04 | 0.19 | 0.47 | −0.66 | 1.12
ISCH | Trial-specific | SCD-HeFT | 0.56 | 0.10 | 0.38 | 0.77 | 0.55 | 0.14 | 0.26 | 0.81
TRT*AGE [65,75) | Trial-specific | AVID | - | - | - | - | −0.15 | 0.32 | −0.86 | 0.47
TRT*AGE [65,75) | Trial-specific | CABG-PATCH | - | - | - | - | 0.23 | 0.23 | −0.24 | 0.70
TRT*AGE [65,75) | Trial-specific | CASH | - | - | - | - | 0.53 | 0.37 | −0.18 | 1.27
TRT*AGE [65,75) | Trial-specific | DEFINITE | - | - | - | - | 0.14 | 0.43 | −0.82 | 1.01
TRT*AGE [65,75) | Trial-specific | MADIT-I | - | - | - | - | 0.08 | 0.43 | −0.73 | 0.89
TRT*AGE [65,75) | Trial-specific | MADIT-II | - | - | - | - | −0.16 | 0.29 | −0.77 | 0.43
TRT*AGE [65,75) | Trial-specific | MUSTT | - | - | - | - | −0.23 | 0.40 | −1.05 | 0.52
TRT*AGE [65,75) | Trial-specific | SCD-HeFT | - | - | - | - | 0.27 | 0.20 | −0.10 | 0.66
TRT*AGE ≥ 75 | Trial-specific | AVID | - | - | - | - | 0.25 | 0.33 | −0.42 | 0.91
TRT*AGE ≥ 75 | Trial-specific | CABG-PATCH | - | - | - | - | 0.48 | 0.35 | −0.23 | 1.14
TRT*AGE ≥ 75 | Trial-specific | CASH | - | - | - | - | −0.13 | 0.64 | −1.40 | 1.04
TRT*AGE ≥ 75 | Trial-specific | DEFINITE | - | - | - | - | −0.31 | 0.54 | −1.44 | 0.64
TRT*AGE ≥ 75 | Trial-specific | MADIT-I | - | - | - | - | −0.37 | 0.73 | −1.93 | 0.91
TRT*AGE ≥ 75 | Trial-specific | MADIT-II | - | - | - | - | −0.05 | 0.33 | −0.69 | 0.59
TRT*AGE ≥ 75 | Trial-specific | MUSTT | - | - | - | - | −0.11 | 0.50 | −1.17 | 0.80
TRT*AGE ≥ 75 | Trial-specific | SCD-HeFT | - | - | - | - | −0.20 | 0.29 | −0.76 | 0.36
TRT*EF > 30% | Trial-specific | AVID | - | - | - | - | 0.27 | 0.27 | −0.30 | 0.79
TRT*EF > 30% | Trial-specific | CABG-PATCH | - | - | - | - | −0.22 | 0.29 | −0.75 | 0.36
TRT*EF > 30% | Trial-specific | CASH | - | - | - | - | 0.41 | 0.34 | −0.24 | 1.11
TRT*EF > 30% | Trial-specific | DEFINITE | - | - | - | - | −0.05 | 0.71 | −1.64 | 1.23
TRT*EF > 30% | Trial-specific | MADIT-I | - | - | - | - | −0.24 | 0.65 | −1.66 | 0.93
TRT*EF > 30% | Trial-specific | MADIT-II | - | - | - | - | −0.04 | 0.87 | −1.91 | 1.56
TRT*EF > 30% | Trial-specific | MUSTT | - | - | - | - | −0.21 | 0.48 | −1.10 | 0.71
TRT*EF > 30% | Trial-specific | SCD-HeFT | - | - | - | - | 0.28 | 0.20 | −0.10 | 0.68
TRT*NYHA II | Trial-specific | AVID | - | - | - | - | −0.17 | 0.31 | −0.78 | 0.44
TRT*NYHA II | Trial-specific | CABG-PATCH | - | - | - | - | 0.37 | 0.29 | −0.17 | 0.93
TRT*NYHA II | Trial-specific | CASH | - | - | - | - | −0.01 | 0.41 | −0.77 | 0.81
TRT*NYHA II | Trial-specific | DEFINITE | - | - | - | - | 0.19 | 0.40 | −0.56 | 1.06
TRT*NYHA II | Trial-specific | MADIT-I | - | - | - | - | 0.25 | 0.42 | −0.58 | 1.08
TRT*NYHA II | Trial-specific | MADIT-II | - | - | - | - | −0.16 | 0.29 | −0.69 | 0.37
TRT*NYHA II | Trial-specific | MUSTT | - | - | - | - | −0.60 | 0.48 | −1.56 | 0.35
TRT*NYHA II | Trial-specific | SCD-HeFT | - | - | - | - | −0.49 | 0.38 | −1.12 | 0.24
TRT*NYHA III | Trial-specific | AVID | - | - | - | - | −0.16 | 0.37 | −0.91 | 0.52
TRT*NYHA III | Trial-specific | CABG-PATCH | - | - | - | - | 0.09 | 0.32 | −0.52 | 0.74
TRT*NYHA III | Trial-specific | CASH | - | - | - | - | 0.70 | 0.46 | −0.13 | 1.70
TRT*NYHA III | Trial-specific | DEFINITE | - | - | - | - | −0.56 | 0.47 | −1.54 | 0.27
TRT*NYHA III | Trial-specific | MADIT-I | - | - | - | - | 0.03 | 0.50 | −1.01 | 0.97
TRT*NYHA III | Trial-specific | MADIT-II | - | - | - | - | −0.26 | 0.28 | −0.80 | 0.29
TRT*NYHA III | Trial-specific | MUSTT | - | - | - | - | −0.51 | 0.47 | −1.51 | 0.38
TRT*NYHA III | Trial-specific | SCD-HeFT | - | - | - | - | 0.17 | 0.38 | −0.45 | 0.91
TRT*NYHA IV | Trial-specific | AVID | - | - | - | - | 0.25 | 1.49 | −2.75 | 3.10
TRT*NYHA IV | Trial-specific | CABG-PATCH | - | - | - | - | 0.16 | 0.47 | −0.80 | 1.08
TRT*NYHA IV | Trial-specific | CASH | - | - | - | - | 0.31 | 1.42 | −2.58 | 3.16
TRT*NYHA IV | Trial-specific | DEFINITE | - | - | - | - | 0.31 | 1.42 | −2.51 | 2.98
TRT*NYHA IV | Trial-specific | MADIT-I | - | - | - | - | 0.40 | 1.37 | −2.09 | 3.34
TRT*NYHA IV | Trial-specific | MADIT-II | - | - | - | - | 0.80 | 0.47 | −0.12 | 1.70
TRT*NYHA IV | Trial-specific | MUSTT | - | - | - | - | 0.40 | 1.46 | −2.07 | 3.10
TRT*NYHA IV | Trial-specific | SCD-HeFT | - | - | - | - | 0.30 | 1.42 | −2.42 | 3.26
TRT*ISCH | Trial-specific | AVID | - | - | - | - | −0.08 | 0.33 | −0.84 | 0.49
TRT*ISCH | Trial-specific | CABG-PATCH | - | - | - | - | 0.31 | 0.38 | −0.50 | 1.01
TRT*ISCH | Trial-specific | CASH | - | - | - | - | 0.21 | 0.39 | −0.49 | 1.03
TRT*ISCH | Trial-specific | DEFINITE | - | - | - | - | 0.05 | 0.77 | −1.49 | 1.70
TRT*ISCH | Trial-specific | MADIT-I | - | - | - | - | −0.21 | 0.51 | −1.30 | 0.77
TRT*ISCH | Trial-specific | MADIT-II | - | - | - | - | −0.01 | 0.50 | −0.75 | 1.02
TRT*ISCH | Trial-specific | MUSTT | - | - | - | - | 0.01 | 0.55 | −1.02 | 1.20
TRT*ISCH | Trial-specific | SCD-HeFT | - | - | - | - | 0.05 | 0.20 | −0.36 | 0.45

Abbreviations for Appendix Table A22: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ISCH = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; SD = standard deviation; TRT = treatment

For ease of interpretation, in Appendix Table A23 we provide the median hazard ratios and the 95 percent credible intervals for the effect of treatment within the main subgroups defined by the prognostic variables for the individual trials and then for the entire population of trials. We also provide the posterior probability that the hazard ratio for the total mortality reduction from the ICD treatment would be 0.80 or less, as this was considered a clinically important reduction in mortality by members of our technical expert panel. For sensitivity analysis, we also present probabilities when using different clinical cutoffs, that is, of 0.70 and 0.90. So, for example, although the 95 percent credible interval for the overall hazard ratio for the reduction in mortality from ICD implant includes the value of no treatment efficacy (that is, a hazard ratio equal to 1), with 83 percent posterior probability the hazard ratio is 0.80 or less indicating a clinically significant reduction. However, if one looks at the findings for treatment and NHYA class 4 patients we observe that not only there is no evidence of a significant interaction, but that there is only a 49 percent probability that the hazard ratio is 0.80 or less. In Appendix Table A24, we provide the same information (median hazard ratios, 95 percent credible intervals, and posterior probability that the hazard ratio is less or equal to 0.70, 0.80 and 0.90) for each of the 48 subgroups. Again, note that there is no evidence of treatment benefit in the individual subgroups. The probability that the hazard ratio is 0.80 or less however is at least 75 percent in 11 of the subgroups indicated in red in the table.

Appendix Table A23 Hazard ratios for the effect of treatment given main prognostic variables

Variable | Trial | Hazard Ratio | | | Probability HR ≤ 0.70 | Probability HR ≤ 0.80 | Probability HR ≤ 0.90
Variable | Trial | Lower | Median | Upper | Probability HR ≤ 0.70 | Probability HR ≤ 0.80 | Probability HR ≤ 0.90
ICD Effect | AVID | 0.50 | 0.64 | 0.85 | 0.71 | 0.93 | 0.98
ICD Effect | CABG-PATCH | 0.80 | 1.04 | 1.37 | 0.00 | 0.03 | 0.17
ICD Effect | CASH | 0.55 | 0.81 | 1.16 | 0.22 | 0.47 | 0.69
ICD Effect | DEFINITE | 0.36 | 0.58 | 0.90 | 0.78 | 0.92 | 0.97
ICD Effect | MADIT-I | 0.26 | 0.46 | 0.74 | 0.96 | 0.99 | 1.00
ICD Effect | MADIT-II | 0.47 | 0.62 | 0.82 | 0.78 | 0.96 | 0.99
ICD Effect | MUSTT | 0.27 | 0.41 | 0.62 | 0.99 | 1.00 | 1.00
ICD Effect | SCD-HeFT | 0.62 | 0.73 | 0.87 | 0.31 | 0.83 | 0.99
ICD Effect | Overall | 0.41 | 0.64 | 1.02 | 0.64 | 0.83 | 0.93
ICD and Age [65,75) Effect | AVID | 0.24 | 0.58 | 1.29 | 0.69 | 0.81 | 0.88
ICD and Age [65,75) Effect | CABG-PATCH | 0.31 | 0.76 | 1.83 | 0.44 | 0.55 | 0.65
ICD and Age [65,75) Effect | CASH | 0.24 | 0.67 | 1.76 | 0.56 | 0.63 | 0.70
ICD and Age [65,75) Effect | DEFINITE | 0.27 | 0.75 | 1.70 | 0.43 | 0.56 | 0.67
ICD and Age [65,75) Effect | MADIT-I | 0.16 | 0.50 | 1.73 | 0.73 | 0.79 | 0.84
ICD and Age [65,75) Effect | MADIT-II | 0.21 | 0.63 | 1.41 | 0.56 | 0.65 | 0.72
ICD and Age [65,75) Effect | MUSTT | 0.14 | 0.51 | 1.66 | 0.71 | 0.77 | 0.82
ICD and Age [65,75) Effect | SCD-HeFT | 0.51 | 0.96 | 1.79 | 0.19 | 0.31 | 0.43
ICD and Age [65,75) Effect | Overall | 0.30 | 0.67 | 1.48 | 0.55 | 0.68 | 0.79
ICD and Age 75+ Effect | AVID | 0.41 | 0.84 | 2.04 | 0.31 | 0.43 | 0.57
ICD and Age 75+ Effect | CABG-PATCH | 0.38 | 0.96 | 2.51 | 0.26 | 0.35 | 0.44
ICD and Age 75+ Effect | CASH | 0.06 | 0.34 | 1.62 | 0.82 | 0.86 | 0.90
ICD and Age 75+ Effect | DEFINITE | 0.15 | 0.48 | 1.37 | 0.76 | 0.81 | 0.86
ICD and Age 75+ Effect | MADIT-I | 0.05 | 0.32 | 1.72 | 0.82 | 0.86 | 0.89
ICD and Age 75+ Effect | MADIT-II | 0.20 | 0.71 | 1.75 | 0.49 | 0.60 | 0.69
ICD and Age 75+ Effect | MUSTT | 0.13 | 0.56 | 2.16 | 0.62 | 0.68 | 0.73
ICD and Age 75+ Effect | SCD-HeFT | 0.26 | 0.60 | 1.34 | 0.63 | 0.76 | 0.83
ICD and Age 75+ Effect | Overall | 0.24 | 0.57 | 1.31 | 0.68 | 0.78 | 0.86
ICD and EF ≥ 30% Effect | AVID | 0.36 | 0.85 | 2.68 | 0.34 | 0.45 | 0.55
ICD and EF ≥ 30% Effect | CABG-PATCH | 0.19 | 0.49 | 1.20 | 0.81 | 0.90 | 0.93
ICD and EF ≥ 30% Effect | CASH | 0.23 | 0.60 | 1.41 | 0.66 | 0.77 | 0.84
ICD and EF ≥ 30% Effect | DEFINITE | 0.12 | 0.62 | 2.55 | 0.57 | 0.64 | 0.70
ICD and EF ≥ 30% Effect | MADIT-I | 0.07 | 0.36 | 1.74 | 0.79 | 0.82 | 0.85
ICD and EF ≥ 30% Effect | MADIT-II | 0.08 | 0.70 | 4.45 | 0.50 | 0.56 | 0.60
ICD and EF ≥ 30% Effect | MUSTT | 0.13 | 0.51 | 2.05 | 0.66 | 0.72 | 0.77
ICD and EF ≥ 30% Effect | SCD-HeFT | 0.48 | 0.99 | 2.04 | 0.22 | 0.32 | 0.41
ICD and EF ≥ 30% Effect | Overall | 0.27 | 0.62 | 1.57 | 0.62 | 0.73 | 0.80
ICD and NYHA II Effect | AVID | 0.26 | 0.57 | 1.18 | 0.69 | 0.81 | 0.89
ICD and NYHA II Effect | CABG-PATCH | 0.36 | 0.84 | 2.32 | 0.34 | 0.46 | 0.56
ICD and NYHA II Effect | CASH | 0.15 | 0.39 | 0.90 | 0.90 | 0.95 | 0.97
ICD and NYHA II Effect | DEFINITE | 0.38 | 0.78 | 1.51 | 0.37 | 0.53 | 0.64
ICD and NYHA II Effect | MADIT-I | 0.18 | 0.60 | 2.02 | 0.61 | 0.70 | 0.76
ICD and NYHA II Effect | MADIT-II | 0.21 | 0.62 | 1.67 | 0.58 | 0.68 | 0.74
ICD and NYHA II Effect | MUSTT | 0.09 | 0.36 | 1.05 | 0.86 | 0.91 | 0.94
ICD and NYHA II Effect | SCD-HeFT | 0.30 | 0.45 | 0.67 | 0.98 | 1.00 | 1.00
ICD and NYHA II Effect | Overall | 0.24 | 0.55 | 1.24 | 0.72 | 0.82 | 0.88
ICD and NYHA III Effect | AVID | 0.24 | 0.57 | 1.40 | 0.70 | 0.78 | 0.85
ICD and NYHA III Effect | CABG-PATCH | 0.27 | 0.65 | 1.64 | 0.56 | 0.67 | 0.74
ICD and NYHA III Effect | CASH | 0.29 | 0.80 | 1.99 | 0.40 | 0.50 | 0.60
ICD and NYHA III Effect | DEFINITE | 0.14 | 0.37 | 0.82 | 0.92 | 0.97 | 0.98
ICD and NYHA III Effect | MADIT-I | 0.12 | 0.48 | 1.71 | 0.72 | 0.78 | 0.83
ICD and NYHA III Effect | MADIT-II | 0.18 | 0.60 | 1.36 | 0.60 | 0.69 | 0.81
ICD and NYHA III Effect | MUSTT | 0.10 | 0.39 | 1.10 | 0.84 | 0.89 | 0.93
ICD and NYHA III Effect | SCD-HeFT | 0.58 | 0.86 | 1.31 | 0.16 | 0.37 | 0.58
ICD and NYHA III Effect | Overall | 0.26 | 0.58 | 1.33 | 0.68 | 0.80 | 0.87
ICD and NYHA IV Effect | AVID | 0.04 | 0.86 | 14.52 | 0.42 | 0.46 | 0.51
ICD and NYHA IV Effect | CABG-PATCH | 0.20 | 0.70 | 2.06 | 0.50 | 0.58 | 0.66
ICD and NYHA IV Effect | CASH | 0.02 | 0.52 | 10.66 | 0.59 | 0.63 | 0.66
ICD and NYHA IV Effect | DEFINITE | 0.05 | 0.88 | 12.87 | 0.42 | 0.46 | 0.51
ICD and NYHA IV Effect | MADIT-I | 0.05 | 0.66 | 12.46 | 0.52 | 0.56 | 0.59
ICD and NYHA IV Effect | MADIT-II | 0.49 | 1.58 | 5.10 | 0.12 | 0.16 | 0.21
ICD and NYHA IV Effect | MUSTT | 0.06 | 0.86 | 16.81 | 0.42 | 0.47 | 0.52
ICD and NYHA IV Effect | SCD-HeFT | 0.06 | 1.03 | 20.10 | 0.37 | 0.41 | 0.46
ICD and NYHA IV Effect | Overall | 0.21 | 0.81 | 3.17 | 0.41 | 0.49 | 0.56
ICD and Ischemic Effect | AVID | 0.36 | 0.62 | 1.09 | 0.66 | 0.82 | 0.90
ICD and Ischemic Effect | CABG-PATCH | 0.52 | 0.82 | 1.27 | 0.26 | 0.46 | 0.65
ICD and Ischemic Effect | CASH | 0.19 | 0.48 | 1.08 | 0.80 | 0.87 | 0.93
ICD and Ischemic Effect | DEFINITE | 0.12 | 0.67 | 3.42 | 0.53 | 0.61 | 0.67
ICD and Ischemic Effect | MADIT-I | 0.16 | 0.37 | 0.91 | 0.91 | 0.95 | 0.97
ICD and Ischemic Effect | MADIT-II | 0.40 | 0.70 | 1.25 | 0.49 | 0.70 | 0.82
ICD and Ischemic Effect | MUSTT | 0.28 | 0.64 | 1.41 | 0.60 | 0.73 | 0.81
ICD and Ischemic Effect | SCD-HeFT | 0.36 | 0.76 | 1.51 | 0.45 | 0.52 | 0.61
ICD and Ischemic Effect | Overall | 0.31 | 0.63 | 1.30 | 0.63 | 0.75 | 0.85

Abbreviations for Appendix Table A23: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; HR = hazard ratio; ICD = implantable cardioverter defibrillator; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial

Appendix Table A24 Hazard ratios for the effect of treatment given 48 subgroups of prognostic variables

Sub- group | Age Group | EF | NYHA | Isch/ Non- Isch | Control | | ICD | | Hazard Ratio | | | Probability HR ≤ 0.70 | Probability HR ≤ 0.80 | Probability HR ≤ 0.90
Sub- group | Age Group | EF | NYHA | Isch/ Non- Isch | #Subjects | # Events | #Subjects | # Events | Lower | Median | Upper | Probability HR ≤ 0.70 | Probability HR ≤ 0.80 | Probability HR ≤ 0.90
1 | < 65 | <30% | I | Non-Isch | 45 | 9 | 42 | 3 | 0.34 | 0.60 | 1.13 | 0.69 | 0.83 | 0.90
2 | < 65 | <30% | I | Isch | 247 | 39 | 295 | 28 | 0.31 | 0.63 | 1.30 | 0.63 | 0.75 | 0.85
3 | < 65 | <30% | II | Non-Isch | 240 | 33 | 227 | 24 | 0.24 | 0.55 | 1.24 | 0.72 | 0.82 | 0.88
4 | < 65 | <30% | II | Isch | 306 | 96 | 302 | 40 | 0.23 | 0.58 | 1.35 | 0.67 | 0.78 | 0.86
5 | < 65 | <30% | III | Non-Isch | 92 | 21 | 82 | 17 | 0.26 | 0.58 | 1.33 | 0.68 | 0.80 | 0.87
6 | < 65 | <30% | III | Isch | 171 | 68 | 188 | 51 | 0.25 | 0.61 | 1.39 | 0.65 | 0.75 | 0.83
7 | < 65 | <30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.21 | 0.81 | 3.17 | 0.41 | 0.49 | 0.56
8 | < 65 | <30% | IV | Isch | 16 | 6 | 27 | 8 | 0.18 | 0.84 | 3.70 | 0.38 | 0.46 | 0.53
9 | < 65 | ≥30% | I | Non-Isch | 15 | 3 | 9 | 1 | 0.27 | 0.62 | 1.57 | 0.62 | 0.73 | 0.80
10 | < 65 | ≥30% | I | Isch | 173 | 15 | 156 | 10 | 0.26 | 0.65 | 1.57 | 0.57 | 0.68 | 0.77
11 | < 65 | ≥30% | II | Non-Isch | 94 | 10 | 98 | 10 | 0.20 | 0.57 | 1.56 | 0.66 | 0.74 | 0.80
12 | < 65 | ≥30% | II | Isch | 157 | 35 | 135 | 22 | 0.21 | 0.58 | 1.58 | 0.64 | 0.72 | 0.79
13 | < 65 | ≥30% | III | Non-Isch | 23 | 6 | 30 | 1 | 0.21 | 0.60 | 1.72 | 0.63 | 0.73 | 0.79
14 | < 65 | ≥30% | III | Isch | 58 | 19 | 50 | 19 | 0.21 | 0.61 | 1.76 | 0.59 | 0.69 | 0.77
15 | < 65 | ≥30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.17 | 0.85 | 3.60 | 0.38 | 0.47 | 0.54
16 | < 65 | ≥30% | IV | Isch | 2 | 0 | 6 | 1 | 0.17 | 0.91 | 3.72 | 0.36 | 0.42 | 0.49
17 | [65,75) | <30% | I | Non-Isch | 18 | 5 | 20 | 1 | 0.30 | 0.67 | 1.48 | 0.55 | 0.68 | 0.79
18 | [65,75) | <30% | I | Isch | 222 | 53 | 211 | 34 | 0.28 | 0.69 | 1.58 | 0.51 | 0.64 | 0.75
19 | [65,75) | <30% | II | Non-Isch | 74 | 14 | 78 | 14 | 0.23 | 0.61 | 1.50 | 0.63 | 0.72 | 0.81
20 | [65,75) | <30% | II | Isch | 198 | 64 | 249 | 61 | 0.23 | 0.63 | 1.58 | 0.58 | 0.70 | 0.78
21 | [65,75) | <30% | III | Non-Isch | 37 | 17 | 32 | 15 | 0.23 | 0.64 | 1.68 | 0.59 | 0.69 | 0.79
22 | [65,75) | <30% | III | Isch | 128 | 65 | 133 | 49 | 0.25 | 0.65 | 1.77 | 0.55 | 0.67 | 0.75
23 | [65,75) | <30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.21 | 0.87 | 4.25 | 0.37 | 0.45 | 0.52
24 | [65,75) | <30% | IV | Isch | 20 | 4 | 24 | 8 | 0.18 | 0.93 | 4.26 | 0.35 | 0.42 | 0.49
25 | [65,75) | ≥30% | I | Non-Isch | 4 | 3 | 3 | 0 | 0.25 | 0.67 | 1.90 | 0.52 | 0.63 | 0.71
26 | [65,75) | ≥30% | I | Isch | 98 | 17 | 101 | 16 | 0.25 | 0.69 | 2.02 | 0.51 | 0.61 | 0.69
27 | [65,75) | ≥30% | II | Non-Isch | 21 | 5 | 19 | 4 | 0.19 | 0.62 | 1.93 | 0.58 | 0.67 | 0.74
28 | [65,75) | ≥30% | II | Isch | 110 | 35 | 74 | 8 | 0.21 | 0.63 | 1.96 | 0.56 | 0.66 | 0.73
29 | [65,75) | ≥30% | III | Non-Isch | 13 | 1 | 7 | 2 | 0.19 | 0.65 | 1.93 | 0.55 | 0.64 | 0.72
30 | [65,75) | ≥30% | III | Isch | 37 | 17 | 33 | 16 | 0.21 | 0.65 | 2.13 | 0.54 | 0.63 | 0.70
31 | [65,75) | ≥30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.17 | 0.94 | 4.11 | 0.35 | 0.42 | 0.48
32 | [65,75) | ≥30% | IV | Isch | 5 | 3 | 4 | 2 | 0.18 | 0.98 | 4.42 | 0.33 | 0.40 | 0.46
33 | 75+ | <30% | I | Non-Isch | 3 | 2 | 12 | 3 | 0.24 | 0.57 | 1.31 | 0.68 | 0.78 | 0.86
34 | 75+ | <30% | I | Isch | 80 | 21 | 92 | 22 | 0.23 | 0.60 | 1.44 | 0.62 | 0.74 | 0.81
35 | 75+ | <30% | II | Non-Isch | 20 | 8 | 22 | 4 | 0.20 | 0.52 | 1.42 | 0.71 | 0.79 | 0.85
36 | 75+ | <30% | II | Isch | 77 | 28 | 76 | 16 | 0.19 | 0.54 | 1.48 | 0.68 | 0.76 | 0.83
37 | 75+ | <30% | III | Non-Isch | 5 | 4 | 16 | 3 | 0.19 | 0.54 | 1.55 | 0.69 | 0.76 | 0.81
38 | 75+ | <30% | III | Isch | 67 | 35 | 78 | 33 | 0.20 | 0.56 | 1.62 | 0.66 | 0.72 | 0.80
39 | 75+ | <30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.16 | 0.78 | 3.53 | 0.44 | 0.52 | 0.58
40 | 75+ | <30% | IV | Isch | 6 | 1 | 7 | 3 | 0.15 | 0.83 | 3.71 | 0.42 | 0.48 | 0.54
41 | 75+ | ≥30% | I | Non-Isch | 2 | 0 | 1 | 1 | 0.20 | 0.59 | 1.75 | 0.62 | 0.70 | 0.78
42 | 75+ | ≥30% | I | Isch | 42 | 8 | 43 | 7 | 0.20 | 0.60 | 1.80 | 0.61 | 0.69 | 0.75
43 | 75+ | ≥30% | II | Non-Isch | 7 | 4 | 4 | 1 | 0.16 | 0.53 | 1.65 | 0.67 | 0.75 | 0.80
44 | 75+ | ≥30% | II | Isch | 34 | 10 | 36 | 8 | 0.17 | 0.55 | 1.69 | 0.65 | 0.73 | 0.79
45 | 75+ | ≥30% | III | Non-Isch | 3 | 1 | 6 | 0 | 0.15 | 0.55 | 1.98 | 0.64 | 0.72 | 0.77
46 | 75+ | ≥30% | III | Isch | 10 | 5 | 11 | 5 | 0.16 | 0.58 | 1.99 | 0.62 | 0.69 | 0.76
47 | 75+ | ≥30% | IV | Non-Isch | 0 | 0 | 0 | 0 | 0.14 | 0.82 | 3.59 | 0.41 | 0.48 | 0.56
48 | 75+ | ≥30% | IV | Isch | 0 | 0 | 0 | 0 | 0.15 | 0.87 | 3.92 | 0.40 | 0.46 | 0.52

Abbreviations for Appendix Table A24: EF = ejection fraction; HR = hazard ratio; ICD = implantable cardioverter defibrillator; Isch = ischemic; Non-Isch = non-ischemic; NYHA = New York Heart Association

While these results seem to contradict those arising from Appendix Tables A13–A17, we note that this full hierarchical model accounts for a variety of sources of variation not accounted for in the previous models; for example, that the interactions between treatment and say the presence of ischemia may not be the same across trials. But in doing so, we deal with yet another issue in that some prognostic subgroups were not observed in all trials. When accounting for all of these sources of variation, there is no longer evidential support for interactions.

We computed the Deviance Information Criterion (DIC) for all four models and including or not the interactions between treatment and baseline prognostic variables (Appendix Table A25). According to this criterion, models minimizing the DIC are preferred. We thus select the model with trial-specific baseline hazard functions. The full Bayesian hierarchical model is a close second best according to this criterion. Because the full Bayesian hierarchical model accounts for more sources of variation we will utilize it for the upcoming discussions.

Appendix Table A25 Model selection based on Deviance Information Criterion (DIC)

Model | Main Effects Only | Including Interactions
No adjustment for trial effects | 8786.20 | 8743.20
Fixed trial effects | 8712.40 | 8711.30
Random trial effects | 8690.00 | 8710.40
Trial-specific baseline hazard | 8591.17 | 8596.68
Fully hierarchical | 8594.30 | 8598.90

Key points: Combining data from trials improves our inferences by increasing the precision of our estimates as well as the power to detect main effects and interactions. There is a variety of modeling approaches that allow us to combine data from different trials, but they do not necessarily lead to the same inference.

Understanding the underlying model assumptions and limitations is important when interpreting the results from the combined analysis. For example, in this section we observed that some models showed evidence for an interaction between treatment and AGE in the combined analysis. But this evidence arises from models that assume that this interaction is the same across all trials. If this assumption is regarded unreasonable, and we consider instead a model that accounts for the variation of the interaction across trials, then the interaction between treatment and AGE is no longer significant.

Finally, when considering Bayesian estimation, the role of priors should also be examined through a sensitivity analysis. We delay the discussion on the effect of priors to the section on “Analysis of Aggregate vs. Patient-level data,” below.

### Using Registry Data

Appendix Table A26 provides descriptive characteristics of CMS ICD Registry patients. As compared to patients recruited to the actual ICD trials, we note that patients in the registry are older and with worse prognosis. Of particular note is that more than 87 percent of the patients in the CMS ICD Registry are NYHA Class II or greater while these patients represented approximately just two thirds of the trial patients.

Appendix Table A26 Descriptive statistics for CMS ICD registry

Characteristic | | Value
Age
Mean, years | | 72.78
Median, years | | 73.5
Standard deviation, years | | 9.89
Ejection Fraction
Mean, % | | 27.11
Median, % | | 25
Standard deviation, % | | 10.11
NYHA Class
Class I | | 13,812 (11.38 %)
Class II | | 40,441 (33.31%)
Class III | | 59,656 (49.14%)
Class IV | | 6299 (5.19%)
Ischemic Disease
Yes | | 87,055 (71.71%)
No | | 33,968 (27.98%)

Abbreviations for Appendix Table A26: CMS = Centers for Medicare & Medicaid Services; ICD = implantable cardioverter defibrillator

As we discussed before, the current CMS registry does not have overall survival. Thus, we utilized the registry data from the MUSTT study for illustrative purposes. Appendix Table A27 has descriptive statistics for the MUSTT registry. We note that patients in the MUSTT registry also have different characteristics from those in the CMS registry. We also note that only approximately 35 percent of the patients in the MUSTT registry received beta-adrenergic blocking agents perhaps influencing the cohort’s mortality.

Appendix Table A27 Descriptive statistics for MUSTT registry

Characteristic | | Control | ICD
Number of patients | | 1414 | 84
Age | Mean (SD) | 65.1 (9.50) | 63.0 (9.20)
Age | < 65 | 607 (42.93%) | 41 (48.81%)
Age | [65,75) | 618 (43.71%) | 38 (45.24%)
Age | [75,85) | 186 (13.15%) | 5 (5.95%)
Age | ≥ 85 | 3 (0.21%) | 0
Ejection Fraction | Mean (SD) | 28 (7.90) | 27.7 (8.00)
Ejection Fraction | ≤ 30% | 878 (62.09%) | 55 (65.48%)
Ejection Fraction | > 30% | 536 (37.91%) | 29 (34.52%)
Ischemic Disease | Yes | 1414 (100.00%) | 84 (100.00%)
Ischemic Disease | No | 0 | 0
NYHA Class | I | 249 (36.89%) | 18 (51.43%)
NYHA Class | II | 263 (38.96%) | 13 (37.14%)
NYHA Class | III | 162 (24.00%) | 4 (11.43%)
NYHA Class | IV | 1 (0.15%) | 0

* Entries refer to means accompanied by standard deviations for continuous variables, or counts followed by percentages for categorical variables.

Abbreviations for Appendix Table A27: ICD = implantable cardioverter defibrillator; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SD = standard deviation

Appendix Figures A4(a) and A4(b) show the posterior predictive survival distribution for the ICD and control groups along with the empirical survival distribution from the registry data in two subgroups. For these subgroups, there are few patients in the MUSTT registry who received an ICD. Control patients in the MUSTT registry have better survival earlier on, but more comparable (to the posterior predictive survival) in later years.

Appendix Figure A4 (a) Posterior predictive survival distributions under the ICD and control group for hypothetical patients with age [65,75), ejection fraction < 30%, NYHA II and ischemic disease and empirical survival distribution from corresponding registry patients in the MUSTT registry

Appendix Figure A4 (b) Posterior predictive survival distributions under the ICD and control group (for hypothetical patients with age 75+, ejection fraction < 30%, NYHA II and ischemic disease and empirical survival distribution from corresponding registry patients in the MUSTT registry

Key points: The above analysis illustrates that we can utilize Bayesian hierarchical models to predict survival from patients in subgroups. This was an illustration and not a definitive examination of the strengths and weaknesses of the Bayesian approach to this problem. Indeed, in this data set we observed that the predictions from the Bayesian model were not always consistent with the survival observed in the registry. Various interpretations of this observation are possible, among them being the possibility (independent of the particular statistical model being employed) that patients in the registry had a different prognosis than patients in the clinical trials.

### Analysis of Aggregate versus Patient-level Data

Appendix Figure A5(a) (see also Appendix Table A28) shows the results from the analysis that combines aggregate data sequentially mimicking when the trials were completed and their data available. Trials were combined in the following order (based on their publication date): MADIT-I, AVID, CABG-PATCH, MUSTT, CASH, MADIT-II, DEFINITE, SCD-HeFT.

Appendix Figure A5 (a) Posterior estimates (mean along with 95% posterior credible intervals) using aggregate data by number of combined trials. In this figure, each set of four vertical lines corresponds to results under the same number of combined trials, but under different models and prior assumptions. Model 1 (dashed lines) refers to a fixed-effects formulation, while model 2 (full lines) refers to a random-effects formulation. Corresponding prior densities are shown in the left-hand side of the figure. Prior 1 (red) has precision 1 while prior 2 (blue) has precision 20

Appendix Figure A5 (b) Posterior estimates (mean along with 95% posterior credible intervals) using patient-level data by number of combined trials. In this figure, each set of four vertical lines corresponds to results under the same number of combined trials, but under different models and prior assumptions. Model 1 (dashed lines) refers to a fixed-effects formulation, while model (full line) 2 refers to a random-effects formulation. Corresponding prior densities are shown in the left-hand side of the figure. Prior 1 (red) has precision 1 while prior 2 (blue) has precision 5

Appendix Table A28 Posterior estimates from Bayesian models, with fixed-effect and random-effects formulation, using aggregate data by number of combined trials. We utilize two priors: prior 1 has precision 1, while prior 2 has precision 20

Trials were combined in the following order (based on their publication date): MADIT-I, AVID, CABG-PATCH, MUSTT, CASH, MADIT-II, DEFINITE, SCD-HeFT.

Trials Combined | Prior 1 | | | | | | | | Prior 2
Trials Combined | Fixed Effect | | | | Random Effects | | | | Fixed Effect | | | | Random Effects
Trials Combined | Esti- mate | SD | 95% Credible Interval | | Esti- mate | SD | 95% Credible Interval | | Esti- mate | SD | 95% Credible Interval | | Esti- mate | SD | 95% Credible Interval
1 | −0.45 | 0.75 | −1.91 | 1.07 | −0.41 | 0.81 | −1.94 | 1.30 | −0.13 | 0.21 | −0.53 | 0.27 | −0.13 | 0.21 | −0.54 | 0.29
2 | −0.47 | 0.63 | −1.70 | 0.77 | −0.47 | 0.62 | −1.66 | 0.84 | −0.20 | 0.19 | −0.58 | 0.18 | −0.20 | 0.19 | −0.56 | 0.18
3 | −0.32 | 0.53 | −1.37 | 0.74 | −0.34 | 0.53 | −1.35 | 0.73 | −0.15 | 0.18 | −0.50 | 0.18 | −0.16 | 0.17 | −0.50 | 0.18
4 | −0.44 | 0.48 | −1.38 | 0.50 | −0.46 | 0.45 | −1.34 | 0.46 | −0.24 | 0.16 | −0.56 | 0.09 | −0.24 | 0.17 | −0.56 | 0.09
5 | −0.37 | 0.44 | −1.24 | 0.49 | −0.40 | 0.39 | −1.14 | 0.38 | −0.22 | 0.16 | −0.53 | 0.08 | −0.23 | 0.16 | −0.54 | 0.08
6 | −0.38 | 0.41 | −1.18 | 0.43 | −0.41 | 0.34 | −1.05 | 0.27 | −0.25 | 0.15 | −0.54 | 0.04 | −0.25 | 0.15 | −0.54 | 0.04
7 | −0.38 | 0.38 | −1.13 | 0.37 | −0.42 | 0.30 | −1.02 | 0.19 | −0.26 | 0.14 | −0.54 | 0.02 | −0.26 | 0.14 | −0.54 | 0.01
8 | −0.38 | 0.36 | −1.10 | 0.35 | −0.40 | 0.27 | −0.94 | 0.13 | −0.26 | 0.13 | −0.52 | 0.00 | −0.26 | 0.13 | −0.53 | 0.00

Abbreviations for Appendix Table A28: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; SD = standard deviation

The figure shows that both fixed and random effects models give similar estimates. The estimates are lower and more precise when using the more informative prior 2. As we accumulate data from trials, the 95 percent posterior credible intervals under both priors get narrower. The gain of information with accumulated data is greater under the less informative prior 1 than under prior 2. Upon combining aggregate data from all trials, there is only a borderline evidence of overall ICD efficacy under prior 2. We do not rule out no efficacy under prior 1.

In contrast, Appendix Figure A5(b) (see also Appendix Table A29) shows the results from the analysis that combines patient-level data sequentially. Estimates from the fixed and random effects models are different when considering data from the first trial only (MADIT-1) which also has the smallest sample size. This shows sensitivity to both models and priors. However, as we combine data from more trials, the estimates become more similar and precise. Moreover, using the more informative prior we would have concluded overall ICD efficacy sooner with six trials.

Appendix Table A29 Posterior estimates from Bayesian models, with fixed-effect and random-effects formulation, using patient-level data by number of combined trials. We utilize two priors: prior 1 has precision 1, while prior 2 has precision 5

Trials were combined in the following order (based on their publication date): MADIT-I, AVID, CABG-PATCH, MUSTT, CASH, MADIT-II, DEFINITE, SCD-HeFT.

Trials Combined | Prior 1 | | | | | | | | Prior 2
Trials Combined | Fixed Effect | | | | Random Effects | | | | Fixed Effect | | | | Random Effects
Trials Combined | Esti- mate | SD | 95% Credible Interval | | Esti- mate | SD | 95% Credible Interval | | Esti- mate | SD | 95% Credible Interval | | Esti- mate | SD | 95% Credible Interval
1 | −0.94 | 0.27 | −1.49 | −0.43 | −0.46 | 0.75 | −1.79 | 1.15 | −0.82 | 0.23 | −1.27 | −0.39 | −0.37 | 0.36 | −1.02 | 0.33
2 | −0.40 | 0.70 | −1.73 | 1.06 | −0.49 | 0.59 | −1.62 | 0.66 | −0.40 | 0.32 | −1.06 | 0.21 | −0.45 | 0.29 | −0.99 | 0.15
3 | −0.27 | 0.62 | −1.52 | 0.96 | −0.33 | 0.46 | −1.24 | 0.67 | −0.36 | 0.29 | −0.94 | 0.20 | −0.30 | 0.25 | −0.79 | 0.19
4 | −0.38 | 0.57 | −1.51 | 0.75 | −0.45 | 0.40 | −1.26 | 0.35 | −0.44 | 0.27 | −0.95 | 0.10 | −0.43 | 0.23 | −0.88 | 0.03
5 | −0.40 | 0.54 | −1.46 | 0.68 | −0.42 | 0.34 | −1.08 | 0.25 | −0.44 | 0.25 | −0.92 | 0.04 | −0.39 | 0.20 | −0.76 | 0.04
6 | −0.35 | 0.50 | −1.31 | 0.65 | −0.40 | 0.28 | −0.95 | 0.13 | −0.45 | 0.23 | −0.91 | 0.00 | −0.40 | 0.18 | −0.73 | −0.04
7 | −0.39 | 0.49 | −1.34 | 0.58 | −0.43 | 0.26 | −0.97 | 0.14 | −0.48 | 0.22 | −0.89 | −0.04 | −0.41 | 0.17 | −0.74 | −0.06
8 | −0.42 | 0.44 | −1.31 | 0.46 | −0.42 | 0.23 | −0.85 | 0.06 | −0.45 | 0.20 | −0.84 | −0.05 | −0.39 | 0.16 | −0.70 | −0.08

Abbreviations for Appendix Table A29: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; SD = standard deviation

Some additional comments are in order. The informative prior used in Appendix Figure A5(b) has precision 5 while the informative prior used to produce the results shown in Appendix Figure A5(a) has precision 20. Thus, to reach a conclusion of overall treatment effect using aggregate data would require an even more informative prior! However, Appendix Figure A5(a) also shows that the results are more sensitive to prior 2 as the estimates are pulled towards the prior mean (zero). Now, when using the patient-level data, the point estimates under both priors are similar, but with higher precision under prior 2.

Appendix Figure A6 (see also Appendix Table A30) shows the results from the analysis that combines patient-level data sequentially but accounting for covariates, under two priors, the same utilized to produce Appendix Figure A5(b), but considering the full Bayesian hierarchical model. Here too we can see that under the more informative prior we would have concluded overall ICD efficacy after six trials. However, under neither prior, we would be able to conclude treatment-covariate interactions across subgroups.

Appendix Figure A6 Posterior estimates (mean along with 95% posterior credible intervals) for the overall treatment effect from Bayesian hierarchical models with covariate adjustment and using patient-level data by number of combined trials. In this figure, each set of two vertical lines corresponds to results under the same number of combined trials, but under different prior assumptions. Corresponding prior densities are shown in the left-hand side of the figure. Prior 1 (navy blue) has precision 1 for the model parameters, while prior 2 (brown) has precision 5

Appendix Table A30 Population parameter estimates from Bayesian hierarchical models, with or without interactions, by number of combined trials with categorized covariates. We utilized two priors: prior 1 has precision 1, while prior 2 has precision 5

Trials were combined in the following order (based on their publication date): MADIT-I, AVID, CABG-PATCH, MUSTT, CASH, MADIT-II, DEFINITE, SCD-HeFT.

No. of trials | Variable | Prior 1 | | | | | | | | Prior 2
No. of trials | Variable | Main Effects Only | | | | Interactions | | | | Main Effects Only | | | | Interactions
No. of trials | Variable | Estimate | SD | 95% Credible Interval | | Estimate | SD | 95% Credible Interval | | Estimate | SD | 95% Credible Interval | | Estimate | SD | 95% Credible Interval
1 | TRT | −0.40 | 0.78 | −1.79 | 1.26 | −0.22 | 0.90 | −1.95 | 1.56 | −0.38 | 0.35 | −1.05 | 0.32 | −0.25 | 0.40 | −1.02 | 0.54
1 | AGE [65,75) | 0.25 | 0.74 | −1.26 | 1.64 | 0.24 | 0.75 | −1.30 | 1.63 | 0.18 | 0.35 | −0.52 | 0.85 | 0.17 | 0.35 | −0.50 | 0.86
1 | AGE ≥ 75 | 0.23 | 0.78 | −1.30 | 1.81 | 0.26 | 0.77 | −1.32 | 1.72 | 0.15 | 0.37 | −0.60 | 0.89 | 0.15 | 0.37 | −0.56 | 0.89
1 | EF > 30% | −0.32 | 0.77 | −1.80 | 1.26 | −0.34 | 0.78 | −1.85 | 1.28 | −0.26 | 0.37 | −0.99 | 0.47 | −0.23 | 0.39 | −1.03 | 0.50
1 | NYHA II | 0.18 | 0.76 | −1.32 | 1.64 | 0.14 | 0.74 | −1.31 | 1.59 | 0.10 | 0.34 | −0.56 | 0.78 | 0.04 | 0.36 | −0.70 | 0.75
1 | NYHA III | 0.60 | 0.80 | −1.04 | 2.10 | 0.51 | 0.81 | −1.16 | 2.00 | 0.44 | 0.37 | −0.29 | 1.14 | 0.43 | 0.38 | −0.30 | 1.12
1 | NYHA IV | −0.03 | 1.04 | −2.09 | 1.92 | 0.00 | 1.02 | −2.05 | 1.99 | −0.02 | 0.46 | −0.91 | 0.95 | −0.01 | 0.44 | −0.89 | 0.79
1 | ISCH | −0.59 | 0.89 | −2.18 | 1.30 | −0.67 | 0.94 | −2.36 | 1.31 | −0.46 | 0.42 | −1.23 | 0.38 | −0.43 | 0.42 | −1.23 | 0.44
1 | TRT*AGE [65,75) | - | - | - | - | 0.05 | 0.75 | −1.46 | 1.49 | - | - | - | - | 0.06 | 0.39 | −0.67 | 0.83
1 | TRT*AGE ≥ 75 | - | - | - | - | −0.43 | 0.91 | −2.20 | 1.28 | - | - | - | - | −0.13 | 0.44 | −0.98 | 0.77
1 | TRT*EF > 30% | - | - | - | - | −0.04 | 0.84 | −1.65 | 1.53 | - | - | - | - | −0.18 | 0.41 | −0.98 | 0.62
1 | TRT*NYHA II | - | - | - | - | 0.40 | 0.85 | −1.26 | 1.93 | - | - | - | - | 0.16 | 0.40 | −0.59 | 0.97
1 | TRT*NYHA III | - | - | - | - | 0.36 | 0.84 | −1.23 | 1.94 | - | - | - | - | 0.07 | 0.39 | −0.72 | 0.84
1 | TRT*NYHA IV | - | - | - | - | 0.02 | 1.02 | −1.87 | 2.11 | - | - | - | - | −0.03 | 0.44 | −0.86 | 0.81
1 | TRT*ISCH | - | - | - | - | −0.39 | 0.89 | −2.09 | 1.39 | - | - | - | - | −0.25 | 0.42 | −1.09 | 0.56
2 | TRT | −0.48 | 0.55 | −1.56 | 0.69 | −0.43 | 0.71 | −1.81 | 1.05 | −0.39 | 0.29 | −0.93 | 0.19 | −0.40 | 0.32 | −0.99 | 0.24
2 | AGE [65,75) | 0.27 | 0.61 | −0.99 | 1.42 | 0.29 | 0.58 | −0.86 | 1.43 | 0.23 | 0.28 | −0.32 | 0.76 | 0.19 | 0.29 | −0.41 | 0.72
2 | AGE ≥ 75 | 0.42 | 0.60 | −0.89 | 1.56 | 0.38 | 0.61 | −0.92 | 1.60 | 0.33 | 0.29 | −0.24 | 0.88 | 0.27 | 0.31 | −0.33 | 0.85
2 | EF > 30% | −0.41 | 0.60 | −1.55 | 0.85 | −0.38 | 0.62 | −1.50 | 0.84 | −0.41 | 0.29 | −0.98 | 0.15 | −0.38 | 0.30 | −0.94 | 0.24
2 | NYHA II | 0.35 | 0.59 | −0.86 | 1.56 | 0.27 | 0.60 | −0.91 | 1.49 | 0.20 | 0.29 | −0.43 | 0.74 | 0.19 | 0.31 | −0.44 | 0.78
2 | NYHA III | 0.78 | 0.64 | −0.58 | 1.87 | 0.74 | 0.66 | −0.71 | 1.97 | 0.60 | 0.31 | −0.01 | 1.20 | 0.59 | 0.30 | −0.02 | 1.17
2 | NYHA IV | 0.00 | 1.00 | −1.84 | 1.96 | 0.02 | 0.97 | −1.88 | 1.82 | 0.00 | 0.42 | −0.87 | 0.83 | −0.03 | 0.46 | −0.97 | 0.85
2 | ISCH | 0.10 | 0.64 | −1.18 | 1.34 | −0.08 | 0.69 | −1.44 | 1.28 | −0.07 | 0.30 | −0.63 | 0.49 | −0.05 | 0.31 | −0.66 | 0.58
2 | TRT*AGE [65,75) | - | - | - | - | 0.00 | 0.60 | −1.17 | 1.21 | - | - | - | - | 0.06 | 0.32 | −0.58 | 0.72
2 | TRT*AGE ≥ 75 | - | - | - | - | −0.06 | 0.73 | −1.58 | 1.34 | - | - | - | - | 0.16 | 0.35 | −0.54 | 0.87
2 | TRT*EF > 30% | - | - | - | - | −0.02 | 0.63 | −1.29 | 1.22 | - | - | - | - | 0.02 | 0.34 | −0.69 | 0.68
2 | TRT*NYHA II | - | - | - | - | 0.14 | 0.65 | −1.16 | 1.38 | - | - | - | - | 0.05 | 0.31 | −0.55 | 0.63
2 | TRT*NYHA III | - | - | - | - | 0.09 | 0.63 | −1.17 | 1.27 | - | - | - | - | 0.07 | 0.32 | −0.53 | 0.70
2 | TRT*NYHA IV | - | - | - | - | 0.01 | 0.97 | −1.86 | 1.92 | - | - | - | - | 0.04 | 0.46 | −0.91 | 0.92
2 | TRT*ISCH | - | - | - | - | −0.12 | 0.70 | −1.46 | 1.24 | - | - | - | - | −0.15 | 0.32 | −0.80 | 0.47
3 | TRT | −0.31 | 0.45 | −1.23 | 0.57 | −0.48 | 0.60 | −1.62 | 0.71 | −0.28 | 0.25 | −0.75 | 0.23 | −0.41 | 0.30 | −0.97 | 0.19
3 | AGE [65,75) | 0.39 | 0.48 | −0.57 | 1.24 | 0.30 | 0.46 | −0.62 | 1.18 | 0.34 | 0.24 | −0.14 | 0.77 | 0.28 | 0.25 | −0.19 | 0.74
3 | AGE ≥ 75 | 0.53 | 0.49 | −0.46 | 1.43 | 0.35 | 0.52 | −0.70 | 1.45 | 0.42 | 0.27 | −0.13 | 0.95 | 0.28 | 0.26 | −0.21 | 0.79
3 | EF > 30% | −0.39 | 0.45 | −1.25 | 0.57 | −0.33 | 0.47 | −1.23 | 0.67 | −0.34 | 0.25 | −0.85 | 0.14 | −0.33 | 0.26 | −0.85 | 0.16
3 | NYHA II | 0.39 | 0.47 | −0.52 | 1.27 | 0.30 | 0.47 | −0.70 | 1.23 | 0.29 | 0.23 | −0.17 | 0.71 | 0.20 | 0.25 | −0.32 | 0.67
3 | NYHA III | 0.80 | 0.49 | −0.30 | 1.71 | 0.81 | 0.51 | −0.31 | 1.70 | 0.72 | 0.26 | 0.20 | 1.21 | 0.65 | 0.27 | 0.13 | 1.16
3 | NYHA IV | 0.22 | 0.73 | −1.32 | 1.65 | 0.16 | 0.73 | −1.31 | 1.52 | 0.21 | 0.35 | −0.51 | 0.88 | 0.16 | 0.36 | −0.55 | 0.85
3 | ISCH | −0.59 | 0.75 | −1.96 | 1.11 | −0.50 | 0.59 | −1.60 | 0.72 | −0.41 | 0.32 | −1.03 | 0.23 | −0.46 | 0.30 | −1.03 | 0.19
3 | TRT*AGE [65,75) | - | - | - | - | 0.11 | 0.52 | −0.92 | 1.17 | - | - | - | - | 0.10 | 0.27 | −0.42 | 0.60
3 | TRT*AGE ≥ 75 | - | - | - | - | 0.21 | 0.60 | −1.07 | 1.32 | - | - | - | - | 0.29 | 0.31 | −0.32 | 0.87
3 | TRT*EF > 30% | - | - | - | - | −0.05 | 0.51 | −1.10 | 0.93 | - | - | - | - | −0.07 | 0.29 | −0.61 | 0.50
3 | TRT*NYHA II | - | - | - | - | 0.21 | 0.55 | −0.94 | 1.28 | - | - | - | - | 0.17 | 0.29 | −0.40 | 0.73
3 | TRT*NYHA III | - | - | - | - | 0.11 | 0.53 | −0.87 | 1.12 | - | - | - | - | 0.08 | 0.29 | −0.49 | 0.63
3 | TRT*NYHA IV | - | - | - | - | 0.06 | 0.77 | −1.45 | 1.58 | - | - | - | - | 0.08 | 0.37 | −0.62 | 0.85
3 | TRT*ISCH | - | - | - | - | −0.14 | 0.58 | −1.28 | 0.96 | - | - | - | - | −0.07 | 0.29 | −0.65 | 0.50
4 | TRT | −0.44 | 0.41 | −1.27 | 0.47 | −0.44 | 0.63 | −1.71 | 0.75 | −0.41 | 0.23 | −0.84 | 0.03 | −0.30 | 0.34 | −0.97 | 0.35
4 | AGE [65,75) | 0.34 | 0.38 | −0.41 | 1.08 | 0.29 | 0.39 | −0.47 | 1.08 | 0.28 | 0.21 | −0.14 | 0.67 | 0.27 | 0.21 | −0.17 | 0.68
4 | AGE ≥ 75 | 0.37 | 0.42 | −0.49 | 1.15 | 0.24 | 0.40 | −0.62 | 1.02 | 0.32 | 0.23 | −0.13 | 0.76 | 0.22 | 0.24 | −0.26 | 0.70
4 | EF > 30% | −0.46 | 0.43 | −1.27 | 0.44 | −0.38 | 0.40 | −1.13 | 0.49 | −0.42 | 0.23 | −0.87 | 0.04 | −0.41 | 0.22 | −0.83 | 0.05
4 | NYHA II | 0.44 | 0.38 | −0.37 | 1.24 | 0.40 | 0.38 | −0.41 | 1.15 | 0.32 | 0.22 | −0.11 | 0.73 | 0.29 | 0.21 | −0.17 | 0.70
4 | NYHA III | 0.92 | 0.40 | 0.09 | 1.68 | 0.95 | 0.41 | 0.10 | 1.68 | 0.76 | 0.23 | 0.27 | 1.19 | 0.74 | 0.23 | 0.26 | 1.15
4 | NYHA IV | 0.21 | 0.76 | −1.38 | 1.65 | 0.23 | 0.78 | −1.33 | 1.71 | 0.18 | 0.35 | −0.55 | 0.87 | 0.15 | 0.36 | −0.59 | 0.85
4 | ISCH | −0.25 | 0.51 | −1.26 | 0.81 | −0.37 | 0.52 | −1.39 | 0.76 | −0.53 | 0.30 | −1.13 | 0.07 | −0.48 | 0.29 | −1.02 | 0.08
4 | TRT*AGE [65,75) | - | - | - | - | 0.03 | 0.44 | −0.79 | 0.88 | - | - | - | - | 0.02 | 0.27 | −0.51 | 0.58
4 | TRT*AGE ≥ 75 | - | - | - | - | 0.14 | 0.55 | −1.10 | 1.12 | - | - | - | - | 0.23 | 0.28 | −0.34 | 0.77
4 | TRT*EF > 30% | - | - | - | - | −0.12 | 0.46 | −1.04 | 0.74 | - | - | - | - | −0.06 | 0.27 | −0.55 | 0.45
4 | TRT*NYHA II | - | - | - | - | −0.02 | 0.47 | −1.01 | 0.94 | - | - | - | - | 0.06 | 0.26 | −0.48 | 0.54
4 | TRT*NYHA III | - | - | - | - | −0.09 | 0.45 | −0.96 | 0.82 | - | - | - | - | −0.03 | 0.26 | −0.57 | 0.48
4 | TRT*NYHA IV | - | - | - | - | 0.07 | 0.74 | −1.41 | 1.55 | - | - | - | - | 0.08 | 0.39 | −0.64 | 0.88
4 | TRT*ISCH | - | - | - | - | −0.04 | 0.60 | −1.23 | 1.11 | - | - | - | - | −0.20 | 0.33 | −0.83 | 0.44
5 | TRT | −0.40 | 0.35 | −1.08 | 0.27 | −0.78 | 0.44 | −1.63 | 0.10 | −0.38 | 0.20 | −0.79 | 0.00 | −0.62 | 0.25 | −1.12 | −0.10
5 | AGE [65,75) | 0.42 | 0.33 | −0.24 | 1.03 | 0.36 | 0.31 | −0.25 | 0.98 | 0.34 | 0.19 | −0.03 | 0.71 | 0.28 | 0.20 | −0.10 | 0.67
5 | AGE ≥ 75 | 0.47 | 0.35 | −0.25 | 1.16 | 0.36 | 0.37 | −0.36 | 1.01 | 0.38 | 0.23 | −0.08 | 0.83 | 0.30 | 0.22 | −0.14 | 0.74
5 | EF > 30% | −0.42 | 0.33 | −1.05 | 0.23 | −0.43 | 0.33 | −1.09 | 0.19 | −0.39 | 0.20 | −0.77 | 0.02 | −0.40 | 0.22 | −0.81 | 0.01
5 | NYHA II | 0.47 | 0.30 | −0.10 | 1.12 | 0.44 | 0.33 | −0.24 | 1.05 | 0.34 | 0.19 | −0.07 | 0.69 | 0.33 | 0.21 | −0.12 | 0.72
5 | NYHA III | 1.04 | 0.36 | 0.28 | 1.65 | 1.02 | 0.36 | 0.28 | 1.65 | 0.85 | 0.21 | 0.40 | 1.22 | 0.82 | 0.24 | 0.33 | 1.24
5 | NYHA IV | 0.21 | 0.72 | −1.21 | 1.52 | 0.18 | 0.75 | −1.31 | 1.65 | 0.18 | 0.34 | −0.49 | 0.84 | 0.16 | 0.35 | −0.55 | 0.82
5 | ISCH | −0.35 | 0.44 | −1.25 | 0.49 | −0.48 | 0.44 | −1.40 | 0.39 | −0.47 | 0.25 | −0.95 | 0.05 | −0.48 | 0.24 | −0.93 | −0.02
5 | TRT*AGE [65,75) | - | - | - | - | 0.13 | 0.38 | −0.61 | 0.87 | - | - | - | - | 0.17 | 0.22 | −0.29 | 0.59
5 | TRT*AGE ≥ 75 | - | - | - | - | 0.13 | 0.48 | −0.89 | 1.02 | - | - | - | - | 0.23 | 0.28 | −0.34 | 0.76
5 | TRT*EF > 30% | - | - | - | - | 0.01 | 0.40 | −0.81 | 0.81 | - | - | - | - | 0.01 | 0.25 | −0.47 | 0.51
5 | TRT*NYHA II | - | - | - | - | 0.06 | 0.40 | −0.72 | 0.89 | - | - | - | - | 0.03 | 0.25 | −0.46 | 0.52
5 | TRT*NYHA III | - | - | - | - | 0.12 | 0.42 | −0.65 | 0.96 | - | - | - | - | 0.11 | 0.26 | −0.43 | 0.61
5 | TRT*NYHA IV | - | - | - | - | 0.10 | 0.78 | −1.50 | 1.58 | - | - | - | - | 0.08 | 0.36 | −0.62 | 0.81
5 | TRT*ISCH | - | - | - | - | 0.22 | 0.43 | −0.59 | 1.07 | - | - | - | - | 0.09 | 0.25 | −0.42 | 0.60
6 | TRT | −0.42 | 0.30 | −0.96 | 0.21 | −0.52 | 0.43 | −1.41 | 0.31 | −0.39 | 0.18 | −0.74 | −0.01 | −0.65 | 0.29 | −1.19 | −0.06
6 | AGE [65,75) | 0.44 | 0.28 | −0.15 | 1.01 | 0.41 | 0.28 | −0.17 | 0.95 | 0.38 | 0.17 | 0.03 | 0.72 | 0.35 | 0.19 | −0.04 | 0.72
6 | AGE ≥ 75 | 0.57 | 0.32 | −0.12 | 1.19 | 0.52 | 0.32 | −0.12 | 1.11 | 0.49 | 0.19 | 0.08 | 0.86 | 0.42 | 0.20 | 0.02 | 0.80
6 | EF > 30% | −0.36 | 0.31 | −0.97 | 0.27 | −0.39 | 0.31 | −0.97 | 0.26 | −0.37 | 0.19 | −0.72 | 0.04 | −0.40 | 0.21 | −0.79 | 0.02
6 | NYHA II | 0.40 | 0.27 | −0.15 | 0.94 | 0.41 | 0.29 | −0.18 | 0.96 | 0.30 | 0.18 | −0.06 | 0.65 | 0.29 | 0.18 | −0.07 | 0.63
6 | NYHA III | 1.01 | 0.29 | 0.43 | 1.58 | 1.01 | 0.30 | 0.43 | 1.56 | 0.85 | 0.18 | 0.48 | 1.21 | 0.81 | 0.19 | 0.42 | 1.15
6 | NYHA IV | 0.48 | 0.62 | −0.92 | 1.63 | 0.25 | 0.62 | −0.99 | 1.40 | 0.41 | 0.30 | −0.19 | 0.98 | 0.27 | 0.29 | −0.33 | 0.86
6 | ISCH | −0.40 | 0.43 | −1.27 | 0.45 | −0.66 | 0.42 | −1.48 | 0.22 | −0.41 | 0.25 | −0.92 | 0.11 | −0.57 | 0.23 | −1.02 | −0.08
6 | TRT*AGE [65,75) | - | - | - | - | 0.08 | 0.32 | −0.54 | 0.72 | - | - | - | - | 0.11 | 0.21 | −0.29 | 0.53
6 | TRT*AGE ≥ 75 | - | - | - | - | 0.12 | 0.39 | −0.67 | 0.95 | - | - | - | - | 0.18 | 0.25 | −0.34 | 0.65
6 | TRT*EF > 30% | - | - | - | - | 0.01 | 0.42 | −0.79 | 0.79 | - | - | - | - | 0.05 | 0.25 | −0.43 | 0.54
6 | TRT*NYHA II | - | - | - | - | 0.00 | 0.36 | −0.72 | 0.73 | - | - | - | - | 0.02 | 0.22 | −0.44 | 0.44
6 | TRT*NYHA III | - | - | - | - | 0.03 | 0.36 | −0.70 | 0.76 | - | - | - | - | 0.07 | 0.22 | −0.34 | 0.49
6 | TRT*NYHA IV | - | - | - | - | 0.39 | 0.65 | −0.95 | 1.63 | - | - | - | - | 0.31 | 0.35 | −0.36 | 0.99
6 | TRT*ISCH | - | - | - | - | −0.01 | 0.41 | −0.76 | 0.89 | - | - | - | - | 0.10 | 0.28 | −0.47 | 0.62
7 | TRT | −0.43 | 0.25 | −0.92 | 0.11 | −0.47 | 0.55 | −1.45 | 0.63 | −0.42 | 0.17 | −0.76 | −0.09 | −0.57 | 0.25 | −1.03 | −0.08
7 | AGE [65,75) | 0.45 | 0.26 | −0.07 | 0.95 | 0.35 | 0.25 | −0.12 | 0.85 | 0.41 | 0.17 | 0.08 | 0.72 | 0.34 | 0.17 | −0.02 | 0.66
7 | AGE ≥ 75 | 0.65 | 0.28 | 0.09 | 1.18 | 0.59 | 0.30 | 0.00 | 1.20 | 0.57 | 0.19 | 0.18 | 0.93 | 0.50 | 0.20 | 0.13 | 0.90
7 | EF > 30% | −0.37 | 0.29 | −0.96 | 0.21 | −0.37 | 0.31 | −0.97 | 0.23 | −0.36 | 0.19 | −0.73 | 0.03 | −0.36 | 0.19 | −0.73 | 0.03
7 | NYHA II | 0.33 | 0.26 | −0.18 | 0.84 | 0.25 | 0.29 | −0.37 | 0.80 | 0.24 | 0.16 | −0.07 | 0.55 | 0.20 | 0.19 | −0.16 | 0.55
7 | NYHA III | 0.96 | 0.26 | 0.44 | 1.45 | 0.96 | 0.28 | 0.38 | 1.48 | 0.82 | 0.18 | 0.46 | 1.17 | 0.83 | 0.19 | 0.47 | 1.20
7 | NYHA IV | 0.47 | 0.63 | −0.85 | 1.59 | 0.30 | 0.62 | −0.99 | 1.42 | 0.42 | 0.30 | −0.17 | 0.96 | 0.29 | 0.30 | −0.32 | 0.89
7 | ISCH | −0.47 | 0.42 | −1.31 | 0.35 | −0.57 | 0.43 | −1.40 | 0.27 | −0.35 | 0.26 | −0.89 | 0.15 | −0.38 | 0.21 | −0.81 | 0.03
7 | TRT*AGE [65,75) | - | - | - | - | 0.13 | 0.31 | −0.50 | 0.75 | - | - | - | - | 0.11 | 0.20 | −0.28 | 0.50
7 | TRT*AGE ≥ 75 | - | - | - | - | 0.03 | 0.36 | −0.71 | 0.71 | - | - | - | - | 0.14 | 0.23 | −0.31 | 0.58
7 | TRT*EF > 30% | - | - | - | - | −0.01 | 0.40 | −0.79 | 0.78 | - | - | - | - | 0.01 | 0.23 | −0.44 | 0.46
7 | TRT*NYHA II | - | - | - | - | 0.10 | 0.32 | −0.50 | 0.76 | - | - | - | - | 0.06 | 0.22 | −0.37 | 0.47
7 | TRT*NYHA III | - | - | - | - | −0.04 | 0.33 | −0.67 | 0.62 | - | - | - | - | 0.00 | 0.21 | −0.41 | 0.42
7 | TRT*NYHA IV | - | - | - | - | 0.34 | 0.66 | −1.00 | 1.59 | - | - | - | - | 0.30 | 0.32 | −0.34 | 0.93
7 | TRT*ISCH | - | - | - | - | −0.12 | 0.52 | −1.21 | 0.84 | - | - | - | - | 0.04 | 0.26 | −0.47 | 0.54
8 | TRT | −0.43 | 0.23 | −0.88 | 0.02 | −0.50 | 0.30 | −1.07 | 0.12 | −0.41 | 0.15 | −0.71 | −0.11 | −0.67 | 0.24 | −1.12 | −0.19
8 | AGE [65,75) | 0.45 | 0.21 | 0.02 | 0.85 | 0.41 | 0.21 | −0.01 | 0.83 | 0.39 | 0.15 | 0.08 | 0.68 | 0.36 | 0.16 | 0.05 | 0.67
8 | AGE ≥ 75 | 0.60 | 0.26 | 0.09 | 1.11 | 0.62 | 0.27 | 0.07 | 1.13 | 0.56 | 0.17 | 0.24 | 0.89 | 0.53 | 0.19 | 0.16 | 0.90
8 | EF > 30% | −0.41 | 0.26 | −0.89 | 0.14 | −0.41 | 0.27 | −0.94 | 0.17 | −0.41 | 0.17 | −0.73 | −0.06 | −0.43 | 0.18 | −0.78 | −0.07
8 | NYHA II | 0.27 | 0.22 | −0.20 | 0.68 | 0.36 | 0.24 | −0.11 | 0.83 | 0.18 | 0.17 | −0.16 | 0.48 | 0.20 | 0.16 | −0.13 | 0.52
8 | NYHA III | 0.92 | 0.24 | 0.44 | 1.37 | 1.01 | 0.24 | 0.55 | 1.45 | 0.78 | 0.17 | 0.44 | 1.10 | 0.79 | 0.17 | 0.44 | 1.12
8 | NYHA IV | 0.44 | 0.61 | −0.85 | 1.61 | 0.33 | 0.62 | −0.92 | 1.55 | 0.42 | 0.32 | −0.21 | 1.03 | 0.29 | 0.31 | −0.29 | 0.90
8 | ISCH | −0.07 | 0.34 | −0.77 | 0.58 | −0.01 | 0.34 | −0.69 | 0.61 | −0.16 | 0.22 | −0.62 | 0.27 | −0.22 | 0.20 | −0.61 | 0.15
8 | TRT*AGE [65,75) | - | - | - | - | 0.08 | 0.26 | −0.48 | 0.58 | - | - | - | - | 0.12 | 0.19 | −0.27 | 0.49
8 | TRT*AGE ≥ 75 | - | - | - | - | −0.06 | 0.32 | −0.72 | 0.55 | - | - | - | - | 0.06 | 0.22 | −0.36 | 0.48
8 | TRT*EF > 30% | - | - | - | - | 0.02 | 0.33 | −0.63 | 0.64 | - | - | - | - | 0.05 | 0.22 | −0.40 | 0.48
8 | TRT*NYHA II | - | - | - | - | −0.09 | 0.30 | −0.65 | 0.47 | - | - | - | - | 0.09 | 0.19 | −0.29 | 0.48
8 | TRT*NYHA III | - | - | - | - | −0.05 | 0.30 | −0.64 | 0.54 | - | - | - | - | 0.12 | 0.21 | −0.26 | 0.55
8 | TRT*NYHA IV | - | - | - | - | 0.31 | 0.65 | −0.99 | 1.65 | - | - | - | - | 0.28 | 0.33 | −0.37 | 0.92
8 | TRT*ISCH | - | - | - | - | 0.04 | 0.33 | −0.63 | 0.68 | - | - | - | - | 0.08 | 0.23 | −0.37 | 0.51

Abbreviations for Appendix Table A30: AVID = Antiarrhythmics Versus Implantable Defibrillators trial; CABG-PATCH = Coronary Artery Bypass Graft-Patch trial; CASH = Cardiac Arrest Study Hamburg trial; DEFINITE = Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation trial; EF = ejection fraction; ISCH = ischemic; MADIT-I = Multicenter Automatic Defibrillator Implantation Trial-I; MADIT-II = Multicenter Automatic Defibrillator Implantation Trial-II; MUSTT = Multicenter Unsustained Tachycardiac Trial; NYHA = New York Heart Association; SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial; SD = standard deviation; TRT = treatment

Key points: In this section we examined the use of patient-level data versus aggregate data as information accrues over time. Our analysis showed that the resulting inferences are not necessarily the same. Moreover, the analysis of aggregate data may be more sensitive to priors.

Finally, we note that the above analysis which assesses the interactions between treatment and covariates defining the subgroups of interest may not be feasible with aggregate data (see Pocock et al.26 for a review on issues with published subgroup analysis).

We now further examine the Bayesian hierarchical model that combines patient-level data from all eight trials. In what follows we will state a sample of questions of clinical interest that we can examine with this model.

Question 1: Is there evidence that the devices used in the different trials differ in terms of their efficacies?

Answer: As we have discussed before, the Bayesian hierarchical model accounts for the variability within and between trials. In particular, we assume that ICD efficacy is trial-specific, but allow for the borrowing of information about ICD efficacy across trials. Appendix Figure A7 shows the estimates of treatment effect for each trial and the overall effect across all trials. There is evidence that treatment efficacy differs across trials. Why this is the case is uncertain. The differences in treatment efficacy could be due to differences in the devices used in the trials, but they could also be due to the patient population being different across trials – even after controlling for age, EF, NYHA class, and ischemia. For example, additional information concerning the QRS interval, gender, or time from myocardial infarction could explain the differences in ICD efficacy. Accounting for these differences, under prior 1 we estimate that the hazard of death in the ICD group is exp(−0.43) = 0.65 times the hazard in the control group. The 95 percent posterior credible interval is 0.41 to 1.02. Under prior 2 we estimate the hazard of death in the ICD group is 0.66 times that in the control group, with a 95 percent posterior credible interval of 0.49 to 0.90. That is, under the more informative prior 2, our analysis supports the evidence of overall ICD efficacy across all trials.

Question 2: Controlling for EF, ischemia, age, and NYHA class, are patients within the available trials similar?

Answer: Another feature of our Bayesian hierarchical model is that it allows for the baseline survival functions to vary from trial-to-trial. Appendix Figure A8 shows the estimated posterior baseline survival functions under each trial and overall trials. Even controlling for EF, ischemia, age, and NYHA class, the figure indicates that patients’ survival differs within the available trials. Patients in the SCDHEFT trial seem to have the best survival prognosis. Patients in CABG-PATCH, AVID and MUSTT have poorer survival prognosis. Again, as discussed under Question 1, there are several potential explanations for this difference. The variation across trials could be due to differences in the implanted devices, in the underlying medical care of the patient populations, or in patient characteristics that are currently not included in our analysis (e.g., gender, QRS interval, time from myocardial infarction). To gain further insight into these differences, additional patient-level data would be required from the trials, and the Bayesian hierarchical model would need to be updated to reflect this additional knowledge. Our group currently has a research grant starting 12/1/09 to gain access to these needed data and to update our Bayesian model so as to allow exploration of these described differences.

Also note that the variation across trials could be due in part to the fact that some of our trials were secondary prevention trials (CASH, AVID), while the remaining trials were primary prevention trials. As we described earlier, we chose to combine data from all ICD trials and explored the effects of the four prognostic characteristics across these populations. However, to explore the potential impact of a patient having previously experienced a sudden cardiac arrest, we have performed additional sensitivity analyses to assess whether treatment may have a different effect in the primary versus secondary patient populations.

First, we considered an analysis, using the Weibull regression model, combining only primary prevention trials or only secondary prevention trials without adjustment for other covariates or trial effects. For comparison purposes, we also combined all trials without adjustment for other covariates or trial effects. The results are reported in Appendix Table A31. The estimated log hazard ratio is essentially the same when combining either only primary prevention trials or only secondary prevention trials. As expected, there is more uncertainty in the estimate when combining secondary prevention trials due to the smaller sample.

Second, we considered an analysis that adjusted for our prognostic variables and included a term to indicate whether or not a trial was of primary or secondary prevention using a Weibull regression model with random trial effects. Appendix Table A32 shows the estimates from the model fit to the data. Our analysis indicated that adding the indicator of primary prevention improves the model fit (p < 0.001). However, while we estimate the hazard of death in primary prevention trials is exp(−0.65)=0.55 times the hazard in secondary prevention trials, the estimate for the hazard of death in the ICD group is exp(−0.37) = 0.69 that for the control group – this estimate is essentially the same as that provided in Appendix Table A16 without adjusting for the indicator of primary prevention trials. Appendix Table A32 also shows that there is no evidence for significant interaction between treatment and the other prognostic variables – including the indicator of primary prevention trial.

Both analyses indicate that, even though the patient populations may be different, there is no evidence for differences in treatment effect. This supports our approach, which combined data from all trials.

Question 3: Is there evidence that the ICD has different effects across patient subgroups?

Answer: The Bayesian hierarchical model also allows for trial-specific interactions. From our analysis (see Appendix Table A30), there was no evidence for overall interactions between treatment and the covariates that define the subgroups of interest. In other words, there was no evidence for treatment-covariate interactions across prognostic subgroups.

Appendix Figure A7 Posterior estimates (mean along with 95% posterior credible intervals) for the overall treatment effect under two priors (prior 2 is more informative than prior 1)

Appendix Figure A8 Estimated posterior baseline survival functions

Appendix Table A31 Estimates from the Weibull regression model (without adjustments)

Trials | Estimate | SE | P-value
Primary prevention trials only | −0.37 | 0.06 | 0.00
Secondary prevention trials only | −0.38 | 0.12 | 0.00
All trials combined | −0.38 | 0.05 | 0.00

Abbreviation for Appendix Table A31: SE = standard error

Appendix Table A32 Estimates from the Weibull regression random-effects model including indicator for primary prevention models

Variable | Main Effects Only | | | Interactions
Variable | Estimate | SE | P-value | Estimate | SE | P-value
TRT | −0.37 | 0.06 | 0.00 | −0.44 | 0.22 | 0.04
PRIMARY | −0.65 | 0.09 | 0.00 | −0.65 | 0.11 | 0.00
AGE [65,75) | 0.49 | 0.06 | 0.00 | 0.44 | 0.08 | 0.00
AGE ≥ 75 | 0.67 | 0.08 | 0.00 | 0.62 | 0.11 | 0.00
EF > 30% | −0.46 | 0.07 | 0.00 | −0.55 | 0.09 | 0.00
NYHA II | 0.35 | 0.08 | 0.00 | 0.41 | 0.10 | 0.00
NYHA III | 1.00 | 0.08 | 0.00 | 0.96 | 0.10 | 0.00
NYHA IV | 0.80 | 0.18 | 0.00 | 0.44 | 0.28 | 0.12
ISCH | 0.48 | 0.07 | 0.00 | 0.50 | 0.10 | 0.00
TRT*PRIMARY | − | − | − | −0.01 | 0.14 | 0.95
TRT*AGE [65,75) | − | − | − | 0.14 | 0.12 | 0.26
TRT*AGE ≥ 75 | − | − | − | 0.13 | 0.16 | 0.43
TRT*EF > 30% | − | − | − | 0.20 | 0.13 | 0.13
TRT*NYHA II | − | − | − | −0.15 | 0.15 | 0.34
TRT*NYHA III | − | − | − | 0.09 | 0.16 | 0.59
TRT*NYHA IV | − | − | − | 0.68 | 0.37 | 0.07
TRT*ISCH | − | − | − | −0.05 | 0.15 | 0.76

Abbreviations for Appendix Table A32: EF = ejection fraction; ISCH = ischemic; NYHA = New York Heart Association; SE = standard error; TRT = treatment

## Methodological and Clinical Implications of Findings

This case study illustrates Situations 1, 2 and 3 (described under CMS contexts). For example, corresponding to Situation 1, in the CASH trial there was no overall efficacy of the ICD, but with a naïve analysis one could find efficacy within the subgroup with patients < 65 years-old, ≤ 30 percent, NYHA class II and ischemic disease. Illustrating Situation 2, the AVID trial supports overall efficacy of the device. However, concern may be raised in the subgroup of patients with < 65 years-old, ≤ 30 percent, NYHA class 3 and ischemic disease, even though the survival comparison within the subgroup was not significant. Finally, illustrating Situation 3, some trials do not have all subgroups represented. For example, the DEFINITE trial was only on non-ischemic patients.

Regarding Situations 1 and 2, testing for interactions at the individual trials often did not support the presence of treatment-covariate interactions. Combining data from the trials improves the power to detect interactions. However, in this case study, the analysis that combined data from the trials generally did not support the presence of interactions. Such conclusions are supported under different model formulations as well as different estimation approaches. In particular, we note that our Bayesian estimation of the models that combined data from trials gave similar estimates to those obtained under the classical frequentist approaches. This illustrates that for large studies, Bayesian inferences are less sensitive to prior choices.

Utilizing the full Bayesian hierarchical model, we simulated the survival experience of hypothetical patients in a new clinical trial. This accounts for both, the variation between and within clinical trials. Because of the borrowing of information across trials, this model allows us to predict survival even if an individual trial does not include some of the subgroups (thus, addressing Situation 3). Using this approach, we note that the survival in the registry data is better (relative to those predicted by our model) in early years. We note, however, that such analysis has an exploratory feature as confounding might be present. We also note that this model could not be estimated using classical frequentist approaches.