# Cirugía para bajar de peso en adultos con diabetes o prediabetes y niveles bajos de obesidad

Revisión de la investigación para adultos con un índice de masa corporal entre 30 y 35

## ¿Es esta información apropiada para mí?

### Si cumple con todas las características siguientes, este resumen es para usted

- Tiene niveles bajos de obesidad, con un índice de masa corporal (IMC) entre 30 y 35.^*^ El IMC es una medida basada en la estatura y el peso que utilizan los médicos para identificar a las personas cuyo peso puede causarles problemas graves de salud.
- Su médico^†^ le ha dicho que usted tiene diabetes o prediabetes (su nivel de azúcar en la sangre está por arriba de lo normal, pero no tanto como en la diabetes).
- Desea saber lo que dicen las investigaciones sobre la cirugía para bajar de peso, llamada también cirugía “bariátrica”, para tratar su diabetes o prediabetes.

### ¿Qué cubrirá este resumen?

Este resumen cubrirá:

- La diabetes, la prediabetes y cómo se tratan
- El IMC y cómo se mide
- Cómo funciona el sistema digestivo
- Qué es la cirugía para bajar de peso y un resumen de tres tipos de esta clase de cirugía: banda gástrica ajustable, gastrectomía en manga y derivación gástrica
- Riesgos de cada tipo de cirugía para bajar de peso
- Qué han encontrado los investigadores sobre la eficacia de la cirugía para bajar de peso para tratar la diabetes o la prediabetes en personas con un IMC entre 30 y 35

Este resumen puede ayudarle a hablar con su médico para determinar si la cirugía para bajar de peso sería apropiada para usted.

Nota: Este resumen no habla sobre cómo prepararse para la cirugía para bajar de peso, ni de lo que puede suceder después de la operación. Hable con su médico si desea mayor información sobre qué hacer antes y después de la operación para bajar de peso.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 54 estudios publicados hasta septiembre de 2012 acerca de la cirugía para bajar de peso en personas con diabetes o prediabetes y con un IMC entre 30 y 35. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/weight-loss-surgery.cfm (disponible sólo en inglés).

Nota: A menudo, los médicos recomiendan la cirugía para bajar de peso a las personas con niveles altos de obesidad. La investigación para este resumen se refiere a la cirugía para bajar de peso en personas con diabetes o prediabetes que tienen un IMC entre 30 y 35.

Hay otras cirugías para bajar de peso además de las que se describen en este resumen. Las cirugías que se explican aquí fueron las estudiadas en las investigaciones para este resumen.

## Conozca su condición

### ¿Qué son la diabetes y la prediabetes?

La diabetes (llamada también “diabetes mellitus”) es una condición en la que el cuerpo tiene dificultad para controlar el nivel de azúcar (o glucosa) presente en la sangre. Esto ocasiona que el azúcar en la sangre aumente demasiado. En la prediabetes, el nivel de azúcar en la sangre es más alto que lo normal, pero no tanto como para llamarlo diabetes. Las personas con prediabetes tienen un riesgo alto de desarrollar diabetes.

El azúcar alta en la sangre puede causar problemas graves de salud; por ejemplo:

- Endurecimiento de las arterias
- Enfermedades del corazón
- Derrame cerebral
- Enfermedad de los riñones
- Ceguera
- Mayor propensión a infecciones
- Pérdida de dedos del pie, los pies, las piernas o los dedos de las manos, a causa de mala circulación e infecciones

Si no se trata, el azúcar alta en la sangre puede causar incluso la muerte.

### ¿Qué tan frecuentes son la diabetes y la prediabetes?

- En Estados Unidos, aproximadamente 8 de cada 100 personas tienen diabetes.
- En Estados Unidos, aproximadamente 33 de cada 100 personas de 20 años en adelante tienen prediabetes.

### ¿Qué es el índice de masa corporal?

El índice de masa corporal (IMC) es una medida basada en la estatura y el peso (conozca su IMC utilizando el diagrama de la página siguiente). El IMC es una de muchas formas en que los médicos identifican a las personas cuyo peso puede causarles problemas graves de salud.

Las personas con un IMC de 30 o más se consideran obesas y corren mayor riesgo de tener problemas de salud. Casi la mitad de los adultos que padecen diabetes tienen un IMC de 30 o más. Este resumen es para las personas con un IMC entre 30 y 35 que tienen diabetes o prediabetes.

### Calcule su IMC

El diagrama siguiente puede ayudarle a calcular su IMC. Primero, localice su estatura a lo largo del lado izquierdo del diagrama. Luego, siga esa línea hasta que encuentre el número más próximo a su peso. Después, siga la columna hasta la parte superior del diagrama para conocer su IMC.

## Conozca sus opciones

### ¿Cómo se tratan la diabetes y la prediabetes?

Su médico puede sugerir varias cosas para ayudar a controlar su diabetes o evitar que empeore su prediabetes. Entre ellas están las siguientes:

- Una alimentación sana
- Ejercicio
- Alcanzar el peso correcto
- Monitoreo del azúcar en la sangre
- Medicamentos

Si usted prueba estos métodos y no logra tener un peso sano y controlar su diabetes o evitar que empeore su prediabetes, su médico puede sugerir una operación para bajar de peso (llamada cirugía “bariátrica”). No deberá considerar la cirugía para bajar de peso, a menos que ya haya tratado con los métodos mencionados y encuentra que no son eficaces.

Este resumen explica lo que han encontrado los investigadores sobre la cirugía para bajar de peso y su uso para el tratamiento de la diabetes o la prediabetes en personas con un IMC entre 30 y 35. En las páginas 7 a 10 se explica qué es la cirugía para bajar de peso y se ofrece un resumen de tres tipos de esta clase de cirugía.

### ¿Cómo funciona el sistema digestivo?

Cuando usted ingiere alimentos, éstos bajan por la garganta, a través de un tubo angosto (llamado esófago) hasta llegar al estómago. Ya en el estómago, los jugos digestivos comienzan a desintegrar el alimento. Desde el estómago, el alimento pasa a la parte inicial del intestino delgado. Aquí, más jugos digestivos apresuran la digestión y se absorben algunas de las calorías y nutrientes. El alimento pasa luego a las partes media y baja de su intestino delgado, donde se absorben el resto de las calorías y nutrientes. Todo alimento que no pueda digerirse pasa del intestino delgado al intestino grueso (también llamado colon), donde permanece en calidad de desecho hasta que sale del cuerpo.

¿Qué son las calorías?

Las calorías se mencionan en la información de nutrición de los alimentos envasados que usted come y le indican cuánta energía hay en una porción de alimento. Usted quema calorías cuando utiliza energía para hacer ejercicio y para otras actividades. Si usted no utiliza todas las calorías que come, la energía sobrante se convierte en grasa y se almacena en su cuerpo.

### ¿Qué es la cirugía para bajar de peso?

La cirugía para bajar de peso es una operación que se hace en el estómago (y a veces en el intestino) para ayudarle a bajar de peso. La cirugía para bajar de peso no es una cirugía para eliminar la grasa.

La cirugía para bajar de peso puede actuar mediante lo siguiente:

- Limitación de la cantidad de alimento que usted puede comer cada vez
- Cambios en la digestión de sus alimentos, de modo que se absorban menos calorías y nutrientes
- Producción de cambios hormonales que reducen el apetito

Además de ayudar a las personas a adelgazar, la cirugía para bajar de peso puede ayudar a controlar la diabetes y evitar que la prediabetes empeore.

Los médicos pueden recomendar la cirugía para bajar de peso a las personas con un IMC arriba de 40. Pueden también sugerir esta clase de cirugía a las personas con un IMC de 35 o más que tengan un problema grave de salud a causa del peso (como diabetes, apnea del sueño o presión arterial alta). Sin embargo, la cirugía para bajar de peso puede ayudar también a las personas con niveles bajos de obesidad (IMC entre 30 y 35) que tengan diabetes o prediabetes.

Tres tipos comunes de cirugía para bajar de peso son:

- Banda gástrica ajustable (Lap-Band Gastric Banding System^®^, Realize Gastric Band^®^)
- Gastrectomía en manga
- Derivación gástrica

Nota: La cirugía para bajar de peso no es una respuesta rápida y fácil al problema de bajar de peso y controlar su diabetes o evitar que su prediabetes empeore. Las personas que se someten a cirugía para bajar de peso deben cambiar su manera de comer y deben hacer ejercicio regular. La cirugía para bajar de peso también conlleva muchos riesgos, que se resumen en la página 10 y 11.

### Resumen de las cirugías para bajar de peso

Banda gástrica ajustable

##### ¿Cómo funciona?

La banda gástrica ajustable disminuye la cantidad de alimento que puede usted comer cada vez. La banda hace que usted se sienta lleno después de comer tan solo una cantidad pequeña.

Después de esta operación, comer demasiado de una sola vez, puede hacer que usted vomite.

##### ¿Cómo se hace?

El cirujano coloca una pequeña banda alrededor de la parte superior del estómago. La banda aprieta el estómago para formar una bolsa pequeña. La banda es ajustable y su médico puede hacerla más estrecha o más amplia, dependiendo de qué tan lleno se sienta usted después de comer, de cuanta hambre tenga y de cuánto peso esté bajando. La banda se llena con agua salada y se conecta a un tubo que desemboca en un puerto. El puerto se coloca dentro del cuerpo, apenas por debajo de la piel. Su médico puede cambiar el tamaño de la banda introduciendo una aguja en el puerto, a través de la piel, y añadiendo o retirando agua salada.

##### ¿Es reversible?

Este tipo de cirugía para bajar de peso es reversible. Un cirujano puede extraer la banda, aunque el procedimiento se puede dificultar por la cicatriz que dejó la primera operación.

Gastrectomía en manga

##### ¿Cómo funciona?

La gastrectomía en manga funciona de dos maneras:

- Disminuye la cantidad de alimento que puede usted comer cada vez
- Produce cambios hormonales que disminuyen su apetito

##### ¿Cómo se hace?

El cirujano elimina la mayor parte del estómago, dejando solamente un tubo estrecho (o “manga”) para que pase el alimento.

##### ¿Es reversible?

Este tipo de cirugía para bajar de peso no es reversible.

Derivación gástrica

##### ¿Cómo funciona?

Una derivación gástrica funciona de tres formas:

- Disminuye la cantidad de alimento que puede usted comer cada vez
- Cambia la forma en que se absorben las calorías y nutrientes del alimento que usted come
- Produce cambios hormonales que disminuyen su apetito

Después de esta operación, comer muchos carbohidratos (almidones), azúcar o grasa puede causar dolor estomacal, cólicos, náusea y diarrea.

##### ¿Cómo se hace?

El cirujano divide el estómago para hacer una pequeña bolsa. Luego, conecta el extremo de la bolsa a la parte media del intestino delgado. Esto significa que cuando usted come, el alimento no pasa por el resto de su estómago ni por la parte inicial de su intestino delgado.

##### ¿Es reversible?

Este tipo de cirugía para bajar de peso no es reversible.

### Cirugía laparoscópica

Estos tres tipos de cirugía para bajar de peso (banda gástrica ajustable, gastrectomía en manga y derivación gástrica) se pueden hacer como cirugía laparoscópica. En la cirugía laparoscópica, el cirujano utiliza un instrumento llamado laparoscopio. El laparoscopio es un tubo delgado con una videocámara minúscula que el cirujano introduce en el abdomen a través de cortes pequeños, además de otros instrumentos pequeños, para hacer la cirugía. El laparoscopio permite al cirujano ver por dentro del cuerpo y realizar la operación sin tener que hacer un corte grande. Esto puede ayudarle a tener una recuperación más rápida.

### ¿Qué riesgos implica la cirugía para bajar de peso?

La cirugía para bajar de peso conlleva muchos riesgos. Algunos de esos riesgos pueden poner en peligro la vida.

Todas las cirugías para bajar de peso implica estos riesgos

- Dolor de estómago, náusea y vómito
- Úlceras del estómago
- Lesión a algún órgano (como los intestinos o el estómago)
- Infección de la herida quirúrgica
- Hemorragia abdominal
- Coágulos de sangre (un coágulo podría viajar al pulmón, poniendo en peligro la vida^*^)

Nota: En algunos casos, las personas pueden no adelgazar después de la cirugía para bajar de peso. También es posible que recuperen el peso que habían bajado.

* Este es un riesgo con cualquier cirugía.

Otros riesgos posibles se indican a continuación para cada tipo de cirugía para bajar de peso.

La banda gástrica ajustable implica estos riesgos

- La banda puede deslizarse de su sitio^*^
- La banda puede incrustarse en el estómago^*^
- Problemas con el tubo que conecta la banda con el puerto
- Problemas con el puerto

* Si esto sucede, puede necesitarse otra operación para arreglar o extraer la banda.

La gastrectomía en manga implica estos riesgos

- Agrava el reflujo de ácido (acidez estomacal)
- Obstrucciones en el estómago por tejido cicatrizal^*^
- Fugas donde se hicieron cortes en el estómago^*^
- Reducción del ancho de la manga creada durante la operación (los síntomas pueden ser náusea, vómito y dificultad para tragar)^†^

* Puede necesitar otra operación para corregirlo.

† Si esto sucede, tal vez el médico deba hacer un procedimiento para ensanchar la manga.

La derivación gástrica implica estos riesgos

- No poder obtener las suficientes vitaminas u otros nutrientes que su cuerpo necesita
- Obstrucciones en sus intestinos por tejido cicatrizal^*^
- Hernia interna (parte de su intestino sobresale por una abertura dentro del abdomen)^*^
- Fugas en los intestinos donde se hicieron cortes durante la operación^*^
- Reducción del ancho de la conexión entre el estómago y el intestino (los síntomas incluyen náusea, vómito y dificultad para tragar)^†^

* Puede necesitar otra operación para corregirlo.

† Si esto sucede, tal vez el médico deba realizar un procedimiento para ensanchar la conexión.

### ¿Qué han encontrado los investigadores acerca de la cirugía para bajar de peso en las personas con diabetes o prediabetes y con un IMC entre 30 y 35?

Los investigadores encontraron que en las personas con diabetes o prediabetes y con un IMC entre 30 y 35:

- Los tres tipos de cirugía para bajar de peso:
  - Ayudaron a bajar de peso (en estudios que duraron hasta 2 años)
  - Ayudaron a controlar la diabetes y a evitar que la prediabetes empeorara (en estudios que duraron hasta 2 años)
  - Al parecer, bajaron el peso y controlaron el azúcar en la sangre mejor que los medicamentos, la dieta y el ejercicio (en estudios que duraron 1 año)
- En algunas personas, la cirugía para bajar de peso empieza a ayudar a bajar el azúcar en la sangre incluso 1 mes después de la operación.

Nota: Después de la cirugía para bajar de peso, es posible que se recupere el peso perdido. También es posible que su diabetes o prediabetes vuelva a empeorar. Es posible que después de la operación tenga que empezar a tomar medicamentos para bajar de peso y tomar de nuevo medicamentos para la diabetes.

### ¿Qué han encontrado los investigadores sobre qué tanto disminuyen el peso y el azúcar en la sangre la cirugía para bajar de peso, la dieta con ejercicio y los medicamentos?

El diagrama siguiente muestra lo que encontraron los investigadores sobre qué tanto disminuyen el peso y el azúcar en la sangre la cirugía para bajar de peso, la dieta con ejercicio y los medicamentos, después de 1 año.

Para evaluar su nivel de azúcar en la sangre, su médico puede hacerle una prueba de sangre HbA1c (hemoglobina A1c). Esta prueba muestra su nivel promedio de azúcar en la sangre en los últimos 2 o 3 meses. En general, el objetivo es que su HbA1c sea menor de 7. Eso significa que su nivel de azúcar en la sangre ha estado en el rango “bueno” en los últimos 2 ó 3 meses. Si su HbA1c es mayor de 7, su azúcar en la sangre está demasiado alta. La cirugía para bajar de peso, la dieta con ejercicio y los medicamentos para la diabetes ayudan todos a bajar su HbA1c.

| Peso después de 1 año | HbA1c (promedio del azúcar en la sangre) después de 1 año
Personas tratadas con cirugía para bajar de peso: | Bajaron 30 a 45 libras^*^ | Bajaron su nivel entre 2.5 y 3.5
Personas tratadas con dieta y ejercicio, sin cirugía: | Bajaron cerca de 6 libras | Bajaron su nivel entre 0.5 y 2
Personas tratadas con medicamentos para la diabetes, sin cirugía: | Bajaron hasta 6 libras o subieron hasta 5 libras, según el medicamento | Bajaron su nivel entre 0.5 y 1

* Se necesita más investigación para saberlo con certeza.

Nota: La cantidad que se disminuya la HbA1c y se adelgace pueden diferir según el tipo específico de cirugía para bajar de peso. No existe suficiente investigación para saber cómo se comparan entre sí los tipos específicos de cirugía para bajar de peso.

Tampoco hay suficientes estudios que comparen directamente la cirugía para bajar de peso con la dieta y el ejercicio o con medicamentos contra la diabetes, para saber cómo se comparan entre sí estas opciones de tratamiento.

Nota: Es importante recordar que las personas que se someten a cirugía para bajar de peso deben cambiar su manera de comer y deben hacer ejercicio regularmente.

### ¿Cuáles son los costos de la cirugía para bajar de peso?

La cirugía para bajar de peso puede costar entre $20,000 y $25,000. Los costos para usted dependen de su seguro médico y del tipo de cirugía que se haga. Su seguro médico puede no cubrir todos los tipos de cirugía para bajar de peso. Consulte a su proveedor de seguro médico para saber si cubren la cirugía para bajar de peso.

## Tome una decisión

### ¿En qué cosas debo pensar?

Se deben considerar varios factores al decidir si la cirugía para bajar de peso es apropiada para tratar la diabetes o prediabetes en su caso particular. Tal vez usted y su médico quieran hablar sobre:

- El balance entre los riesgos y beneficios posibles de la cirugía para bajar de peso
- Los cambios que deberá hacer en su estilo de vida si se somete a una cirugía para bajar de peso
- Si decide tratarse con cirugía para bajar de peso, cuál es la mejor para usted
- Qué piensa respecto a las cirugías para bajar de peso que son difíciles de revertir o no son reversibles
- Cuánto tiempo tendría que ausentarse del trabajo y de otras actividades cotidianas después de la operación
- Los costos de la cirugía para bajar de peso y si su seguro médico la cubre
  - Tal vez quiera considerar cómo se comparan los costos de la cirugía para bajar de peso con los costos de los medicamentos para bajar de peso y de los medicamentos para la diabetes o la prediabetes.

### Pregunte a su médico o cirujano

- ¿Podría la cirugía para bajar de peso ayudarme a controlar mi diabetes o a evitar que mi prediabetes empeore?
- Si no me opero para bajar de peso, ¿cómo controlaremos mi diabetes o evitaremos que empeore mi prediabetes?
- Si la cirugía para bajar de peso puede ayudar, ¿qué tipo de cirugía piensa que sería mejor para mí?
- Si me opero, ¿cuánto tiempo estaré en el hospital? ¿Cuánto tiempo estaré ausente del trabajo y mis actividades diarias?
- ¿De cuáles efectos secundarios graves debo estar pendiente?
- Después de la cirugía, ¿qué cambios tendré que hacer en mi estilo de vida? ¿Necesitaré seguir una dieta determinada? ¿Qué tamaños de porción deberé comer? ¿Cuánto ejercicio necesitaré?
- ¿Cuánto tiempo después de la cirugía tardará en mejorar mi diabetes o prediabetes?
- ¿Voy a necesitar todavía mis medicamentos para la diabetes?

## Fuente

La información de este resumen proviene del informe Bariatric Surgery and Nonsurgical Therapy in Adults With Metabolic Conditions and a Body Mass Index of 30.0 to 34.9 kg/^m2^ (Cirugía bariátrica y tratamiento no quirúrgico en adultos con trastornos metabólicos y un índice de masa corporal de 30.0 a 34.9 kg/^m2^), de junio de 2013.

El informe fue producido por el Southern California Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Sur de California, con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Si desea una copia del informe o más información acerca de la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/weight-loss-surgery.cfm (disponible sólo en inglés).

Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas), en el Baylor College of Medicine (Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por personas con diabetes o prediabetes y un IMC entre 30 y 35 y por personas que se han sometido a cirugía para bajar de peso.

Esta guía fue traducida de la publicación en inglés titulada Weight-Loss Surgery for Adults With Diabetes or Prediabetes Who Are at the Lower Levels of Obesity.

* Si no está seguro de su IMC, consulte el diagrama de la página 4.

† En este resumen, el término “médico” se refiere al profesional de la atención médica que lo atiende, como su médico, gastroenterólogo (especialista en el sistema digestivo), cirujano bariátrico, enfermera o asistente médico.