# Prevención de coágulos después de una cirugía para reemplazar la cadera o rodilla o por una fractura de cadera

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Es apropiada si:

- Está usted considerando o planeando someterse a una cirugía para reemplazo total de cadera o de rodilla o una cirugía por fractura de cadera.
- Es usted adulto (esta información proviene de investigación realizada en adultos).

### ¿Qué cubre este resumen?

Este resumen cubre lo que dicen las investigaciones acerca de los posibles beneficios y efectos secundarios de los tratamientos que ayudan a prevenir la formación de coágulos de sangre después de una operación de cadera o rodilla. Las opciones de tratamiento incluyen medicamentos diluyentes de la sangre y dispositivos que aumentan el flujo de sangre en las piernas (medias elásticas o cubiertas inflables para las piernas o pies). Este resumen puede ayudarle a evaluar esas opciones con su médico.

### ¿De dónde proviene esta información?

La información proviene de un informe en el que se revisaron 179 estudios publicados entre enero de 1980 y mayo de 2011. El informe fue financiado por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal. Si desea obtener una copia del informe completo, visite www.effectivehealthcare.ahrq.gov/thrombo.cfm (disponible sólo en inglés).

## Conozca sobre la formación de coágulos de sangre después de una cirugía

### ¿Qué son los coágulos de sangre?

Cuando se lesiona un vaso sanguíneo, las células de la sangre se unen para formar un coágulo. Este coágulo ayuda a detener el sangrado. Los coágulos de sangre son la combinación de glóbulos sanguíneos, plaquetas (pequeñas células adherentes que aceleran la formación del coágulo) y fibrina (proteína que forma una malla de filamentos que envuelve a las células). Los médicos llaman “trombo” a este tipo de coágulo.

Los coágulos de sangre son buenos cuando ayudan a sellar una herida para que deje de sangrar. Pero a veces, un coágulo de sangre se forma cuando no se necesita. Este tipo de coágulo puede causar problemas de salud o incluso la muerte.

### ¿Qué coágulos de sangre son los más peligrosos?

- Un coágulo de sangre que se forma dentro de una vena grande ubicada en alguna parte profunda del cuerpo se llama “trombosis venosa profunda”, o DVT, por su sigla en inglés. La mayoría de las DVT se producen en los vasos sanguíneos de las pantorrillas o los muslos (vea la imagen de abajo).
- Un coágulo de sangre en los pulmones se llama “embolia pulmonar”, o PE por su sigla en inglés. Un PE puede ser grave y puede causar la muerte.

### ¿Cuál es el riesgo de que se forme un coágulo de sangre después de una cirugía de cadera o de rodilla?

El DVT es el tipo más frecuente de coágulo de sangre que se forma después de una operación por reemplazo total de cadera, reemplazo total de rodilla o fractura de cadera. La mayoría de las personas que se someten a uno de estos tipos de cirugía mayor tienen poca actividad física durante los primeros días o semanas que siguen a la operación. Esto puede ocasionar que el flujo de sangre sea más lento y aumentar el riesgo de que se formen coágulos de sangre. Las personas con DVT pueden no tener ningún síntoma y no saber que tienen el problema.

Hasta 4 de cada 10 personas que no se tratan con medicamentos para prevenir la formación de coágulos desarrollan DVT en el plazo de 1 ó 2 semanas después de haber tenido una cirugía mayor de cadera o de rodilla.

El uso de un medicamento o de un dispositivo para prevenir la formación de coágulos puede reducir a 1 ó 2 personas de cada 10, el riesgo de desarrollar DVT después de una cirugía de cadera o de rodilla.

Las investigaciones encontraron que las personas con insuficiencia cardiaca congestiva (condición que ocurre cuando el corazón no puede bombear suficiente sangre al resto del cuerpo) corrían mayor riesgo de formar coágulos de sangre después de una cirugía mayor de cadera o de rodilla.

### ¿Por qué prevenir la formación de coágulos después de una cirugía de cadera o de rodilla?

- Los coágulos de sangre que se alojan en venas grandes o que están ubicadas en partes profundas (DVT) pueden limitar el flujo de sangre en las piernas y causar dolor e hinchazón.
- Los coágulos que se alojan en los pulmones (PE) pueden causar dolor o dificultar la respiración. En ocasiones pueden causar problemas del corazón o la muerte.
- El DVT puede hacer más lenta la recuperación posterior a la cirugía.
- El DVT puede producir hinchazón de las piernas, aun después de haberse recuperado de la cirugía.

## Conozca sus opciones

Aunque el DVT y PE pueden tratarse, y muchos desaparecen sin tratamiento, su médico o cirujano puede sugerir el uso de dispositivos o medicamentos para ayudar a prevenir la formación de estos coágulos de sangre. Estos tratamientos suelen administrarse poco después de la cirugía.

Dispositivos médicos para prevenir DVT y PE

Dispositivo | Descripción e información
| Medias de compresión | Las medias, hechas de un elástico fuerte, comprimen suavemente la pantorrilla y la pierna para aumentar el flujo de la sangre. Las medias pueden cubrir toda la pierna o llegar sólo hasta la pantorrilla. Las medias que cubren toda la pierna pueden ser difíciles e incómodas de poner y quitar.
| Dispositivos de compresión neumática intermitente | Las cubiertas para las piernas se inflan y desinflan con una bomba de aire, para comprimir las piernas, durante el día y la noche.
| Bombas venosas para los pies | Las cubiertas para los pies se inflan y desinflan con una bomba de aire para aumentar el flujo de sangre en las piernas.

Medicamentos para prevenir DVT y PE

Tipo de medicamento | Nombre genérico (marca comercial) | Cómo se toma
Agentes antiplaquetarios orales | Aspirina | Pastilla o líquido
Heparina de bajo peso molecular (LMWH) | Dalteparina (Fragmin^®^) Enoxaparina (Lovenox^®^) Tinzaparina (Innohep^®^) | Inyección
Heparina no fraccionada (UFH) | Heparina sódica | Inyección
Inhibidores del factor Xa | Fondaparinux (Arixtra^®^) | Inyección
Inhibidores del factor Xa | Rivaroxabán (Xarelto^®^) | Pastilla
Antagonistas de la vitamina K | Warfarina (Coumadin^®^, Jantoven^®^) | Pastilla

### ¿Qué dicen las investigaciones acerca de estos tratamientos?

#### Beneficios

- El principal beneficio tanto de los medicamentos como de los dispositivos es que reducen la posibilidad de que se forme un coágulo de sangre (DVT, PE o cualquier otro tipo de coágulo de sangre).

#### Efectos secundarios

- El principal efecto secundario de los medicamentos que previenen la formación de coágulos de sangre es un pequeño aumento de la probabilidad de hemorragia. La función de estos medicamentos es la de diluir la sangre. Una vez que la sangre se diluye, puede no coagular tan fácilmente si usted sangra. De cada 100 personas que toman medicamentos para prevenir la formación de coágulos, hasta 8 tienen problemas de sangrado. (Para comparar, de cada 100 personas que no toman medicamentos para prevenir la formación de coágulos, hasta 5 tienen problemas de sangrado.)
- Los problemas de sangrado pueden adoptar varias formas:
  - La herida de la cirugía puede sangrar, lo que puede retrasar la recuperación y hacer que se necesite otra operación.
  - Las lesiones que se producen cuando está tomando el medicamento pueden sangrar más de lo normal.
  - El sangrado puede ocurrir dentro del cuerpo y causar problemas graves de salud.

Comparación de los beneficios y efectos secundarios de los dispositivos médicos y los medicamentos

| Beneficios | Efectos secundarios
Todos los medicamentos para prevenir la formación de coágulos | - Las personas que toman medicamentos para prevenir la formación de coágulos de sangre tienen una menor probabilidad de sufrir un DVT que las que no toman medicamentos. | - Las personas que toman medicamentos para prevenir la formación de coágulos de sangre tienen una mayor probabilidad de sangrar que las que no toman medicamentos.
Comparación de medicamentos específicos | - La LMWH disminuye más que la UFH la posibilidad de que se formen coágulos de sangre. | - Las personas que toman LMWH tienen menor probabilidad de sangrar que las que toman UFH.
Comparación de medicamentos específicos | - La LMWH disminuye más que la warfarina (Coumadin^®^) la posibilidad de que se formen ciertos tipos de coágulos de sangre. | - Las personas que toman warfarina (Coumadin^®^) tienen menor probabilidad de sangrar que las que toman LMWH.
Comparación de medicamentos específicos | - El fondaparinux (Arixtra^®^) disminuye más que la LMWH la posibilidad de que se formen ciertos tipos de coágulos de sangre. | - Las personas que toman enoxaparina (Lovenox^®^) tienen una menor probabilidad de sangrar que las que toman fondaparinux (Arixtra^®^).; - La posibilidad de sangrar es casi igual entre el rivaroxabán (Xarelto^®^) y la enoxaparina (Lovenox^®^).
Comparación entre los medicamentos y los dispositivos médicos | - Las personas que toman medicamentos para prevenir la formación de coágulos tienen una menor probabilidad de sufrir un DVT que las que utilizan los dispositivos médicos. | - Las personas que toman medicamentos para prevenir la formación de coágulos tienen una mayor probabilidad de sangrar que las que utilizan los dispositivos médicos.
Comparación de dispositivos médicos específicos | - No existe suficiente investigación para saber si alguno de estos dispositivos reduce más que los otros la posibilidad de que se formen coágulos de sangre. | - No se ha investigado lo suficiente para saber si el uso de alguno de estos dispositivos médicos causa efectos secundarios.
Tomar medicamentos durante 28 días o más | - Tomar medicamentos durante 28 días o más reduce la posibilidad de sufrir un DVT o PE, más que tomarlos durante 7 a 10 días.^*^ | - La probabilidad de sangrar es mayor cuando el medicamento se toma durante 28 días o más que cuando se toma durante 7 a 10 días.^*^

* La mayoría de los estudios se realizaron con personas que se habían sometido a cirugía por reemplazo de cadera o cirugía por fractura de cadera.

DVT = trombosis venosa profunda; LMWH = heparina de bajo peso molecular; PE = embolia pulmonar; UFH = heparina no fraccionada

### Otra información sobre la prevención de coágulos

- Algunas personas que no toman medicamentos para prevenir la formación de coágulos de sangre tienen, no obstante, problemas de sangrado, aunque su riesgo de sangrar es menor.
- La warfarina (Coumadin^®^) tarda por lo menos varios días en funcionar.
  - La sangre deberá analizarse diariamente hasta que el médico se asegure de que se está administrando la cantidad correcta del medicamento. Una vez que se ajuste la dosis del medicamento, se puede analizar la sangre cada 1 a 4 semanas.
  - Es posible que deba ir alguien a su casa a extraerle sangre para este análisis, o que deba usted ir al consultorio o a un laboratorio para que ahí le hagan la prueba de sangre.
- La cantidad de vitamina K que obtenga usted de pastillas o de alimentos deberá ser la misma durante toda la semana. No deberá cambiar la cantidad que toma o que come mientras se trate con warfarina (Coumadin^®^). La vitamina K se encuentra en verduras de hoja verde, como el brócoli, la col rizada, las hojas de repollo o col morada y las colecitas de Bruselas.
- Los medicamentos que se inyectan vienen en jeringas con una sola dosis para que usted mismo se inyecte.
  - Una enfermera u otro profesional de atención médica le enseñará a aplicarse estas inyecciones.
  - Si usted no puede o no se siente cómodo inyectándose, un profesional de atención médica puede inyectarlo en su casa, consultorio o clínica.
- Las medias, los dispositivos de compresión neumática y las bombas para los pies se usan con mayor frecuencia en el hospital. Pueden o no estar cubiertos por su seguro.

## Hable con su médico

### Cómo prevenir la formación de coágulos

Usted y su médico deberán decidir qué medicamento o dispositivo puede ser mejor para prevenir la formación de coágulos de sangre después de una cirugía para reemplazar la cadera o rodilla o por fractura de cadera. Los medicamentos pueden ayudar a prevenir la formación de coágulos de sangre, pero pueden también aumentar un poco el riesgo de sangrado. En la mayoría de las personas, el riesgo de que se forme un coágulo de sangre después de cirugía es más alto que el riesgo de sangrar mientras se toma el medicamento. El tratamiento que sugiera el médico puede depender de varios factores; por ejemplo:

- Las opciones disponibles en el hospital.
- Su historial médico y otras condiciones médicas que tenga.
- Sus riesgos particulares.
- Sus preferencias personales; por ejemplo:
  - Su preocupación de tener DVT o PE.
  - Su preocupación de tener hemorragia.
  - Su preferencia por un medicamento en forma de pastilla o de inyección.
  - Su capacidad para administrarse el medicamento y cómo se ajusta éste a su estilo de vida.

### ¿Qué costo tienen los medicamentos para prevenir la formación de coágulos?

El costo que cada medicamento tenga para usted dependerá de su seguro médico, de la dosis (cantidad) que necesite y si existe el medicamento en forma genérica.

Precios de mayoreo de medicamentos para prevenir coágulos de sangre

Nombre comercial | Presentación | Dosis típica^*^ | Costo del comercial por día | Nombre genérico | Costo del genérico por día
LMWH
Fragmin^®^ | Inyección^†^ | 5,000 unidades una vez al día | $39 | Dalteparina | ND
Innohep^®^ | Inyección^†^ | 20,000 unidades una vez al día | ND | Tinzaparina | ND
Lovenox^®^ | Inyección^†^ | 30 mg/ml dos veces al día 40 mg/ml una vez al día | $60 $40 | Enoxaparina | $48 $32
UFH
Este producto tiene varios nombres. | Inyección^†^ | 5,000 unidades tres veces al día | ND | Heparina | $16
Inhibidores del Factor Xa
Arixtra^®^ | Inyección^†^ | 2.5 mg una vez al día | $64 | Fondaparinux | $11
Xarelto^®^ | Pastilla | 10 mg una vez al día | $9 | Rivaroxabán | ND
Antagonistas de la vitamina K
Coumadin^®^; Jantoven^®^ | Pastilla | 2 mg una vez al día 5 mg una vez al día 10 mg una vez al día | $2; $1 todas las dosis | Warfarina | $1 todas las dosis de ambos nombres comerciales

* La dosis típica es un promedio. Su médico puede prescribir una dosis diferente y puede cambiar varias veces la cantidad que usted toma. Los precios son los precios promedio de mayoreo según el Red Book Online^®^.

† Las dosis de las Inyecciones tienen una de dos medidas diferentes: unidades o mg/ml (miligramos/mililitro).

ND = no disponible

### Pregunte a su médico

- ¿Tengo un riesgo alto de que se formen coágulos después de mi operación?
- ¿Piensa usted que me conviene tomar un medicamento o usar un dispositivo después de mi operación?
- ¿Qué métodos utiliza más usted para prevenir la formación de coágulos después de la cirugía de cadera o de rodilla?
- ¿Por cuánto tiempo debo tomar el medicamento?
- ¿Cuáles son los síntomas de formación de coágulos que debo vigilar?
- ¿Tengo un riesgo alto de sufrir problemas de sangrado?
- ¿A qué síntomas de sangrado debo estar atento?
- Si escogemos un medicamento, ¿necesitaré análisis de sangre? ¿Con qué frecuencia? ¿Puede hacerse en mi casa o tendré que ir al consultorio o a un laboratorio?
- ¿Afectará alguno de estos medicamentos a otros que tomo?
- ¿Cuánto tendré que pagar de mi propio bolsillo por el medicamento?

Otras preguntas:

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

Anote aquí las respuestas:

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

## Fuente

La información de este resumen proviene del informe Venous Thromboembolism Prophylaxis in Orthopedic Surgery (Profilaxis de la tromboembolia venosa en la cirugía ortopédica), de marzo de 2012.

El informe fue producido por el University of Connecticut–Hartford Hospital Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Hospital de la Universidad de Connecticut–Hartford) con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/thrombo.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. El resumen fue revisado por pacientes que se sometieron a cirugía por reemplazo total de cadera o de rodilla.

Esta guía fue traducida de la publicación en inglés titulada Preventing Blood Clots After Hip or Knee Replacement Surgery or Surgery for a Broken Hip: A Review of the Research for Adults.