# Tratamientos no quirúrgicos para controlar la fuga de orina

Revisión de las investigaciones para mujeres

## ¿Es esta información apropiada para mí?

### Es apropiada si

- Usted es una mujer de más de 18 años de edad.
- Tiene dificultad para contener la orina antes de llegar al baño y siente un impulso fuerte de orinar.
- Se le escapa la orina cuando hace ejercicio, estornuda o tose.
- Su médico o enfermera le ha dicho que tiene “incontinencia urinaria”, una condición que le hace sentir la necesidad de orinar de inmediato, no le permite contener la orina o hace que tenga fugas de orina, sin previo aviso.
- Está buscando tratamientos que no necesiten una operación para este problema.

### ¿Qué decisión se debe tomar?

¿Qué tipo de tratamiento debo escoger para que mi incontinencia disminuya o desaparezca: ejercicios, dispositivos o medicamentos?

- Si son ejercicios, ¿cuáles debo hacer?
- Si son dispositivos, ¿cuál debo usar?
- Si son medicamentos, ¿cuál debo tomar?

### ¿Cuáles son los objetivos del tratamiento?

- Lograr “continencia“ o la capacidad de contener la orina hasta llegar al baño.
- Reducir las veces que siente la necesidad de ir al baño inmediatamente.
- Reducir las veces que tiene fugas de orina accidentales.

### ¿Cómo puede este resumen ayudarme a decidir?

La información de este resumen proviene de un informe en el que se revisaron 905 estudios realizados entre enero de 1990 y diciembre de 2011 acerca de los tratamientos sin cirugía para la incontinencia urinaria. Usted puede usar la información de las investigaciones para entender lo que se sabe acerca de los posibles beneficios y efectos secundarios de cada opción de tratamiento. Esta información le ayudará a hablar con su médico sobre cuál podría ser la mejor opción para usted.

## Conozca su condición

### ¿Qué es la incontinencia urinaria?

La incontinencia urinaria (IU), es una condición que hace que la orina se fugue accidentalmente.

Hay dos tipos de IU comunes en las mujeres, dependiendo de los síntomas:

- Incontinencia de esfuerzo: usted no puede “contener“ la orina al toser, estornudar, hacer ejercicio o levantar un objeto. Como resultado, tiene fugas pequeñas o moja la ropa.
- Incontinencia de urgencia: usted siente a menudo un impulso fuerte de orinar y no alcanza a llegar al baño sin que se le fugue la orina. Un problema similar, que se conoce como “vejiga hiperactiva”, ocurre cuando siente un fuerte impulso repentino de orinar o necesita orinar a menudo. Sin embargo, con la vejiga hiperactiva, la persona puede contener la orina.

Algunas mujeres tienen los dos tipos de incontinencia. Los médicos llaman a esto “incontinencia mixta”.

#### ¿Por qué tengo esta condición?

- Muchas cosas pueden haber causado que los músculos que permiten contener la orina (llamados “músculos del piso pélvico”) se hayan debilitado o que usted haya perdido el control de estos músculos. Algunas de esas causas son:
  - Edad avanzada
  - Sobrepeso
  - Embarazo
  - Histerectomía
  - Infecciones frecuentes de las vías urinarias
  - Cesárea previa (operación para dar a luz al bebé)
- El pequeño anillo de músculos que mantienen cerrada la vejiga (“esfínter vesical”) se ha debilitado y permite la fuga de orina.
- Si tiene vejiga hiperactiva, pueder ser que los nervios que controlan los músculos de la vejiga causan espasmos en estos músculos. O bien, los músculos de la vejiga no pueden relajarse lo suficiente para que la vejiga se expanda y pueda almacenar más orina.
- Algunos medicamentos pueden aumentar la posibilidad de tener problemas para controlar la orina. Por ejemplo, los medicamentos para la presión arterial y los antipsicóticos (para tratar condiciones mentales).

#### ¿Por qué debe tratarse la IU?

Tener IU afecta como se sienten la mayoría de las mujeres de sí mismas y limita su capacidad de disfrutar del trabajo o de sus actividades favoritas. La IU no tratada puede ocasionar salpullido e infecciones de las vías urinarias. La buena noticia es que muchas mujeres pueden disminuir o resolver totalmente su incontinencia, con tratamiento.

## Conozca sus opciones

### ¿Cómo se trata la IU?

Existen varios tipos de tratamientos para la IU:

- Ejercicios especiales
- Medicamentos
- Entrenamiento de la vejiga
- Dispositivos médicos

El tipo de ejercicio, dispositivo o medicamento que se use dependerá si se está tratando una IU de esfuerzo, de urgencia o mixta.

La meta de su tratamiento puede ser la continencia (poder controlar la orina) y/o reducir las veces que tenga urgencias o fugas.

Tratamientos para la incontinencia urinaria

Incontinencia de esfuerzo
Ejercicios | - Entrenamiento de los músculos del piso pélvico (PFMT, por su sigla en inglés); - PFMT con biorretroalimentación
Dispositivos médicos | - Estimulación eléctrica; - Estimulación magnética
Medicamentos | - Estrógeno tópico; - Duloxetina (Cymbalta^®^)
Incontinencia de urgencia
Entrenamiento de la vejiga | - Horario para orinar
Dispositivos médicos | - Estimulación percutánea del nervio tibial
Medicamentos | - Oxibutinina (Ditropan^®^); - Solifenacina (VESIcare^®^); - Tolterodina (Detrol^®^); - Fesoterodina (Toviaz^®^); - Darifenacina (Enablex^®^); - Trospio (Sanctura^®^)
Incontinencia mixta
Para tratar la incontinencia mixta, se combinan los tratamientos de la incontinencia de esfuerzo y la incontinencia de urgencia.

#### Ejercicios

- Entrenamiento de los músculos del piso pélvico (PFMT, por su sigla en inglés) llamado también ejercicios de Kegel.
  - Estos ejercicios consisten en apretar y aflojar los músculos que se utilizan para detener la orina.
  - Su médico puede decirle cuántas veces debe apretar y aflojar, y por cuánto tiempo necesitará seguir haciendo estos ejercicios.
  - El entrenamiento de los músculos del piso pélvico incluye a veces biorretroalimentación (en inglés, biofeedback), para ayudar a las mujeres a aprender a hacer los ejercicios. La biorretroalimentación utiliza grabadoras electrónicas u otros instrumentos, y a veces diarios escritos, para anotar las contracciones de sus músculos del piso pélvico o de los músculos de la vejiga.

#### Entrenamiento de la vejiga

- Este método busca aumentar la capacidad para retener la orina por períodos cada vez más largos, siguiendo un horario.
- La meta es lograr un horario que le haga ir al baño solamente una vez cada 3 ó 4 horas.
- Aunque no sienta la necesidad de orinar, debe vaciar la vejiga de acuerdo con el horario planificado.
- Cuando sienta el impulso de orinar fuera de ese horario, tratará de contenerse más minutos cada vez, hasta que pueda seguir el horario.
- Su médico puede ayudarle a establecer un horario de acuerdo a la necesidades específicas de su cuerpo.

#### Dispositivos médicos

- Estimulación eléctrica
  - Se coloca dentro de la vagina un tubo suave de silicona, del tamaño aproximado de un tampón. Se conecta a una unidad accionada por baterías que envía una cantidad pequeña de electricidad al tubo y los músculos que lo rodean.
  - Este tratamiento se puede realizar en casa después de que un terapeuta o enfermera le explica cómo usar el dispositivo y fija un nivel que aplica tensión a los músculos sin ser incómodo.
- Estimulación magnética
  - La paciente se sienta en una silla con bobinas magnéticas en el asiento o debajo de éste. Se envía una corriente eléctrica a las bobinas y así se crea un campo magnético que tensa y relaja los músculos de la pelvis.
  - Este tratamiento se debe hacer en una clínica o consultorio médico. La paciente puede permanecer vestida durante el tratamiento.
- Estimulación percutánea del nervio tibial (PTNS, por su sigla en inglés)
  - La estimulación percutánea del nervio tibial utiliza una aguja fina que se introduce cerca del tobillo.
  - Se transmiten a la aguja pulsos eléctricos que viajan por el nervio tibial, un nervio que sube por la pierna y se conecta con los nervios que controlan los músculos de la vejiga.
  - Este tratamiento se debe hacer en una clínica o consultorio médico.

#### Medicamentos

Los médicos pueden usar varios tipos distintos de medicamentos para ayudar a mejorar la IU, dependiendo del tipo de IU que usted tenga.

#### Medicamentos para la incontinencia de esfuerzo

- Estrógeno. El estrógeno es una hormona femenina. La cantidad que el cuerpo produce de esta hormona disminuye con la edad. El estrógeno tópico se utiliza en la forma de parches para la piel o en forma de crema, tabletas o un anillo que se coloca en la vagina. El estrógeno tópico se vende con muchos nombres comerciales distintos.
- Duloxetina (Cymbalta^®^). Este medicamento ayuda a las personas con depresión, ansiedad y fibromialgia (dolor muscular y cansancio crónicos), pero algunos médicos pueden usarlo también para la incontinencia de esfuerzo.

#### Medicamentos para la incontinencia de urgencia

- Todos los medicamentos que se usan para tratar la incontinencia de urgencia se hicieron para ese propósito. Todos los medicamentos analizados mejoraron la incontinencia de urgencia; por ejemplo, redujeron la frecuencia de fugas o la cantidad de cada fuga. Algunos medicamentos ayudaron a las mujeres a evitar totalmente las fugas de orina.
- Ya que “incontinencia mixta” significa que la mujer tiene incontinencia de esfuerzo y de urgencia, estos medicamentos pueden utilizarse también para la incontinencia mixta.

#### ¿Qué dicen los estudios de investigación acerca de los tratamientos para la IU?

¿Cómo debo interpretar esta información?

Este diagrama ilustra los resultados de las investigaciones y las probabilidades de qué los tratamientos para la incontinencia de esfuerzo o de urgencia puedan mejorar los síntomas o lograr continencia. Las mujeres de color verde obtendrán el beneficio, las de color rojo tendrán efectos secundarios y las de color azul son las que no obtendrán beneficio ni efectos secundarios. Por ejemplo:

[image] | 5 de cada 10 mujeres significa que las probabilidades de que usted obtenga el mismo resultado serán de 50/50.
[image] | 1 de cada 10 mujeres significa que usted tendrá una menor probabilidad de obtener el mismo resultado.

Entre más mujeres de cada 10 hayan tenido un resultado, lo más probable es que usted obtenga ese mismo resultado.

Éstas son estimaciones generales de la probabilidad de que un tratamiento funcione o cause un efecto secundario. Cada persona puede responder de manera diferente. Es posible que tenga que probar varios tratamientos antes de encontrar uno que le funcione.

Opciones para tratar la incontinencia de esfuerzo sin medicamentos

Tratamientos sin medicamentos: ejercicios
Entrenamiento de los músculos del piso pélvico (PFMT, por su sigla en inglés) | Beneficios 3 de cada 10 mujeres recuperaron la continencia utilizando este tratamiento. [image] 4 de cada 10 mujeres mejoraron sus síntomas usando este tratamiento. [image] Efectos secundarios No se sabe, pero la mayoría de los investigadores piensan que, en caso de haberlos, serían pocos.
PFMT con biorretroalimentación | Beneficios Entre 4 y 5 de cada 10 mujeres lograron la continencia utilizando este tratamiento, pero nuevas investigaciones podrían cambiar este resultado. [image] 4 de cada 10 mujeres mejoraron sus síntomas utilizando este tratamiento. [image] Efectos secundarios No se sabe, pero la mayoría de los investigadores piensan que, en caso de haberlos, serían pocos.
Tratamientos sin medicamentos: dispositivos médicos
Estimulación eléctrica | Beneficios 2 de cada 10 mujeres recuperaron la continencia utilizando este tratamiento. [image] 2 de cada 10 mujeres mejoraron sus síntomas utilizando este tratamiento. [image] Efectos secundarios No se sabe, pero la mayoría de los investigadores piensan que, en caso de haberlos, serían pocos.
Estimulación magnética | Beneficios No ayudó a las mujeres a obtener la continencia, pero nuevas investigaciones podrían cambiar este resultado. 3 de cada 10 mujeres lograron mejoría de sus síntomas con este tratamiento, pero las investigaciones son limitadas. [image] Efectos secundarios No se sabe, pero la mayoría de los investigadores piensan que, en caso de haberlos, serían pocos.
Medicamentos para tratar la incontinencia de esfuerzo
Estrógeno tópico | Beneficios No existe suficiente investigación para saber si el estrógeno mejoró la IU. Efectos secundarios No existe suficiente investigación para saber si el estrógeno utilizado para tratar la IU causa efectos secundarios.
Duloxetina (Cymbalta^®^) | Beneficios Menos de 1 de cada 10 mujeres redujo sus síntomas utilizando este medicamento. [image] Efectos secundarios Aproximadamente 2 de cada 10 mujeres tuvieron náuseas al usar este medicamento. [image] 1 de cada 10 mujeres tuvo resequedad en la boca al usar este medicamento. [image] Entre 1/2 y 1 de cada 10 mujeres tuvo estreñimiento, sueño excesivo, insomnio (incapacidad para conciliar el sueño o mantenerse dormida) y mareo al usar este medicamento. [image]

Opciones para tratar la incontinencia de urgencia

Tratamientos sin medicamentos: cambios en el estilo de vida
Entrenamiento de la vejiga | Beneficios No se reportó el número de mujeres que recuperaron la continencia. 4 de cada 10 mujeres aliviaron sus síntomas con ejercicios para el control de la vejiga. [image] La combinación de PFMT y entrenamiento de la vejiga mejoró la continencia en mujeres con incontinencia de urgencia. Efectos secundarios No se sabe, pero la mayoría de los investigadores piensan que, en caso de haberlos, serían pocos.
Tratamientos sin medicamentos: dispositivos médicos
Estimulación percutánea del nervio tibial | Beneficios No se informó el número de mujeres que recuperaron la continencia. 3 de cada 10 mujeres aliviaron sus síntomas con este dispositivo. [image] Efectos secundarios No hubo diferencia entre el número de mujeres que reportaron efectos secundarios con el uso de este dispositivo y las que reportaron efectos secundarios con un tratamiento simulado (no se aplicaba ningún pulso eléctrico, pero se decía a las mujeres que se les estaba administrando tratamiento).
Medicamentos para tratar la incontinencia de urgencia
Darifenacina (Enablex^®^) | Beneficios Aproximadamente 1 de cada 10 mujeres mejoró sus síntomas al usar este medicamento. [image] Efectos secundarios Aproximadamente 2 de cada 10 mujeres tuvieron resequedad en la boca al usar este medicamento. [image] Aproximadamente 1 de cada 10 mujeres tuvo estreñimiento al usar este medicamento. [image] Menos de 1 de cada 10 mujeres tuvo malestar estomacal al usar este medicamento. [image]
Fesoterodina (Toviaz^®^) | Beneficios Aproximadamente 1 de cada 10 mujeres recuperó la continencia al usar este medicamento. [image] Aproximadamente 1 de cada 10 mujeres mejoró sus síntomas al usar este medicamento. [image] Efectos secundarios Aproximadamente 2 de cada 10 mujeres tuvieron resequedad en la boca al usar este medicamento. [image] Menos de 1 de cada 10 mujeres tuvo estreñimiento al usar este medicamento. [image] Menos de 1 de cada 10 mujeres tuvo sequedad ocular al usar este medicamento. [image]
Oxibutinina (Ditropan^®^) | Beneficios Aproximadamente 1 de cada 10 mujeres recuperó la continencia al usar este medicamento. [image] Aproximadamente 2 de cada 10 mujeres mejoró sus síntomas al usar este medicamento. [image] Efectos secundarios Entre 3 y 4 de cada 10 mujeres tuvieron resequedad en la boca al usar este medicamento. [image] Aproximadamente 1 de cada 10 mujeres tuvo malestar estomacal al usar este medicamento. [image] Estreñimiento: ninguna diferencia con las mujeres que tomaron un placebo (pastilla de azúcar).
Solifenacina (VESIcare^®^) | Beneficios Aproximadamente 1 de cada 10 mujeres recuperó la continencia al usar este medicamento. [image] Aproximadamente 2 de cada 10 mujeres mejoraron sus síntomas al usar este medicamento. [image] Efectos secundarios Entre 1 y 2 de cada 10 mujeres tuvieron resequedad en la boca al usar este medicamento. [image] Aproximadamente 1 de cada 10 mujeres tuvo estreñimiento al usar este medicamento. [image] Menos de 1 de cada 10 mujeres tuvo visión borrosa al usar este medicamento. [image]
Tolterodina (Detrol^®^) | Beneficios Aproximadamente 1 de cada 10 mujeres recuperó la continencia al usar este medicamento. [image] Aproximadamente 1 de cada 10 mujeres mejoró sus síntomas al usar este medicamento. [image] Efectos secundarios Aproximadamente 1 de cada 10 mujeres tuvo resequedad en la boca al usar este medicamento. [image] Menos de 1 de cada 10 mujeres tuvo estreñimiento al usar este medicamento. [image] Menos de 1 de cada 10 mujeres tuvo malestar estomacal al usar este medicamento. [image]
Trospio (Sanctura^®^) | Beneficios Aproximadamente 1 de cada 10 mujeres recuperó la continencia al usar este medicamento. [image] Efectos secundarios Aproximadamente 1 de cada 10 mujeres tuvo resequedad en la boca al usar este medicamento. [image] Menos de 1 de cada 10 mujeres tuvo estreñimiento al usar este medicamento. [image] Menos de 1 de cada 10 mujeres tuvo sequedad ocular al usar este medicamento. [image]

Advertencia: los médicos y las pacientes también han informado algunos efectos secundarios graves que pueden ocurrir con estos medicamentos. Aunque no son muy frecuentes, son más peligrosos que los efectos secundarios comunes mencionados antes. Estos efectos secundarios incluyen ritmo cardiaco (latido del corazón) irregular y rápido, alucinaciones, dificultad para pensar y rara vez muerte. La posibilidad de tener un efecto secundario grave es mayor entre las pacientes de edad avanzada, en las que toman muchos medicamentos diferentes al mismo tiempo, y en las que toman algunos antihistamínicos (medicamentos contra la alergia) y antibióticos, junto con estos medicamentos para la IU. Pregunte a su médico acerca de estos efectos secundarios más graves.

#### ¿Cómo se comparan entre sí los medicamentos para la IU?

- La fesoterodina (Toviaz^®^) es mejor que la tolterodina (Detrol^®^) para disminuir la intensidad y frecuencia del impulso de orinar, pero también podría ser más propensa que la tolterodina a causar efectos secundarios negativos. La fesoterodina (Toviaz^®^) podría también ser mejor para detener totalmente cualquier escape, pero no se ha hecho suficiente investigación para saberlo con seguridad.
- La oxibutinina (Ditropan^®^) no fue mejor que la tolterodina (Detrol^®^) para prevenir cualquier escape, pero podría ser más propensa que la tolterodina a causar efectos secundarios negativos.
- No existe suficiente investigación para señalar con certeza las diferencias entre el uso de varios medicamentos combinados y el uso de cada uno por separado.
- Más de la mitad de todas las personas que toman medicamentos para la IU dejan de tomarlos después de 1 año de tratamiento, casi siempre por los efectos secundarios.
- La oxibutinina (Ditropan^®^), el trospio (Sanctura^®^) y la darifenacina (Enablex^®^) funcionan en mujeres de todas las edades, incluso en las mayores de 65 años.
- El trospio (Sanctura^®^) funciona en mujeres obesas (con mucho sobrepeso). No existe suficiente investigación para saber cómo afecta el sobrepeso excesivo a otros medicamentos.
- Si está usted tomando al mismo tiempo siete o más medicamentos (de cualquier tipo), es más probable que tenga efectos secundarios del trospio (Sanctura^®^).
- Es probable que le funcione la solifenacina (VESIcare^®^), aun cuando no haya obtenido beneficios con otros medicamentos.
- Las dosis más altas de medicamentos son eficaces para las personas que no obtienen resultados la primera vez que prueban un medicamento, con excepción de la solifenacina (VESIcare^®^), pero las dosis más altas también aumentan la probabilidad de que ocurran efectos secundarios.

#### Comparación de los ejercicios con los dispositivos y medicamentos

Ningún estudio de investigación ha comparado los resultados de los ejercicios con los de los dispositivos y los medicamentos. Sin embargo, los ejercicios y los dispositivos médicos parecen dar mejores resultados que los medicamentos, y con menos efectos secundarios negativos, para mejorar los síntomas de IU y ayudar a las mujeres a recuperar la continencia.

#### Cambios en el estilo de vida

Algunas investigaciones encontraron que las mujeres con mucho sobrepeso pudieron mejorar sus síntomas de IU, bajando de peso y haciendo ejercicio.

#### Control de los síntomas de IU

Mientras trata usted la IU, puede hacer lo siguiente para controlar la incontinencia:

- Programe pausas regulares para ir al baño.
- Pida que le dejen trabajar cerca de un baño.
- Use almohadillas absorbentes en la ropa interior.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Se deben considerar varias cosas al elegir un tratamiento para la IU:

- Si su incontinencia le incomoda lo suficiente como para buscar tratamiento.
- Qué tratamiento es el mejor para su tipo particular de IU.
- El balance entre los beneficios y los efectos secundarios posibles de cada tratamiento.
- Qué tratamiento se ajusta mejor a sus preferencias y valores personales.
- Cuántos tratamientos está dispuesta a probar hasta encontrar el mejor para usted.

### ¿Por cuánto tiempo deberé usar los tratamientos?

Es posible que deba usar los tratamientos incluso después de que su IU mejore y aun cuando desaparezca totalmente.

### ¿Cuáles son los costos del tratamiento?

Los costos del tratamiento para usted dependen de varios factores; por ejemplo:

- Su seguro médico. Algunos dispositivos para estimulación pueden no estar cubiertos por Medicare, Medicaid o las compañías de seguro médico privadas. Su copago por medicamentos dependerá también de su plan de medicamentos.
- El ejercicio y el entrenamiento de la vejiga pueden no costar nada, a menos que trabaje usted con una enfermera o fisioterapeuta.
- El tiempo que necesite usar los dispositivos médicos o medicamentos.
- La cantidad (dosis) que necesite tomar del medicamento.
- Si el medicamento existe en la forma genérica. La mayoría de los medicamentos para la IU no existen en forma genérica.

Costos de mayoreo de los medicamentos con receta para la IU

Nombre genérico | Dosis | Costo del suministro para 1 mes^*^ | Nombre comercial | Costo del suministro para 1 mes^*^
Darifenacina | 15 mg al día | ND | Enablex^®^ | $170
Fesoterodina | 4 mg al día | ND | Toviaz^®^ | $151
Oxibutinina | 10 mg al día | $90 | Ditropan^®^ | $152
Solifenacina | 10 mg al día | ND | VESIcare^®^ | $180
Tolterodina | 2 mg dos veces al día | ND | Detrol^®^ | $189
Trospio | 20 mg dos veces al día | $170 | Sanctura^®^ | $193

* Los costos de mayoreo provienen de la página RED BOOK Online^®^. Los precios del medicamento genérico son el promedio de los precios fijados por los diferentes fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los mostrados aquí, dependiendo del fabricante al que compre su farmacia.

ND = no disponible

### Pregunte a su médico

- ¿Qué piensa de las investigaciones sobre los diferentes tratamientos de la IU?
- Considerando mis síntomas de IU, ¿cuál de estas opciones es más probable que me ayude?
- ¿Cuánto tardaré en notar alguna diferencia y cuándo debo consultarlo para probar algo diferente?
- ¿Cómo sabré si estoy teniendo un efecto secundario grave del medicamento y cuándo debo llamarle?

Anote aquí las respuestas

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen proviene del informe Nonsurgical Treatments for Urinary Incontinence in Adult Women: Diagnosis and Comparative Effectiveness (Tratamientos no quirúrgicos para la incontinencia urinaria en mujeres adultas: diagnóstico y comparación de la efectividad), publicado en abril de 2012.

El informe fue producido por el Minnesota Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Minnesota), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/ui.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página web está disponible en http://www.nlm.nih.gov/medlineplus/spanish/.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por mujeres con incontinencia urinaria.

Traducido de la publicación en inglés titulada Non-surgical Treatments for Urinary Incontinence: A Review of the Research for Women