# Terapias para la depresión resistente a tratamiento

Revisión de las investigaciones

## ¿Es esta información apropiada para mí o para la persona a quien cuido?

### Es apropiada si

- Un médico u otro profesional de salud le ha dicho que usted tiene un trastorno depresivo mayor (MDD, por su sigla en inglés) o depresión,
- Ya ha probado dos tipos diferentes de medicamentos para la depresión, pero todavía tiene los síntomas de esta enfermedad.
- Un médico u otro profesional de salud le ha dicho que tiene depresión resistente a tratamiento, conocida también como TRD, por su sigla en inglés.
- Su médico o profesional de salud le ha sugerido uno o más de los siguientes tratamientos (terapias) sin medicamentos:
  □ Terapia electroconvulsiva (ECT, por su sigla en inglés)
  □ Estimulación magnética transcraneal repetitiva (rTMS, por su sigla en inglés)
  □ Estimulación vagal o del nervio vago (VNS, por su sigla en inglés)
  □ Pscioterapia o terapia de conversación

### No es apropiada si

- Un médico no le ha diagnosticado depresión.
- Usted no ha probado por lo menos dos tipos diferentes de medicamentos para tratar la depresión.

### ¿Qué cubre este resumen?

Este resumen explica lo que es la depresión resistente a tratamiento. Le informa lo que indica la investigación más reciente acerca de los tratamientos disponibles cuando los medicamentos no ayudan. También le sugiere preguntas que puede hacer sobre estas opciones de tratamiento.

### ¿De dónde proviene la información?

La información proviene de un informe en que se revisaron 63 estudios publicados entre enero de 1980 y noviembre de 2010, para la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ por su sigla en inglés), una agencia de investigación del gobierno federal. El informe completo puede leerse en www.effectivehealthcare.ahrq.gov/trd.cfm (disponible solo en inglés).

## Conozca su condición

### ¿Por qué no funcionan los medicamentos?

Si sus medicamentos para la depresión no le ayudaron a sentirse mejor, no está usted solo. La mitad o más de todas las personas que tratan su depresión con medicamentos aún tendrán algunos síntomas o volverán a tenerlos.

Si sus síntomas no desaparecen después de haber probado dos o más medicamentos diferentes por un mínimo de 6 semanas, es posible que tenga lo que los médicos llaman “depresión resistente a tratamiento”.

### ¿Por qué tengo depresión resistente a tratamiento?

Pueden haber muchas razones por las que un medicamento les sirve a algunas personas y a otras no. La depresión es una enfermedad compleja y cada persona es diferente. Es posible que su médico o profesional de salud quiera volver a hablar de sus síntomas, para ver si hay otras razones por las que se siente deprimido. Usted y su médico pueden evaluar también otras opciones de tratamiento.

Muchas personas no mejoran la primera o segunda vez que tratan su depresión. ¡No se dé por vencido! Usted y su médico pueden seguir buscando el tratamiento adecuado.

#### ¿Habrá algo que me funcione a mí?

Los médicos conocen muchas maneras distintas de tratar la depresión. Aunque algunos medicamentos no le hayan ayudado a sentirse mejor, existen otras opciones de tratamiento. Entre ellas están el combinar los medicamentos con tratamientos sin medicamentos, agregar otros medicamentos o cambiar a uno o más tratamientos sin medicamentos.

## Conozca sus opciones

### ¿Cuáles son los tratamientos sin medicamentos?

Aunque los medicamentos son el recurso médico más común para tratar la depresión, hay otros tratamientos (terapias) que no usan medicamentos. Los investigadores han estudiado cuatro de estos tratamientos:

#### Terapia electroconvulsiva

La terapia electroconvulsiva, o ECT por su sigla en inglés, es uno de los tratamientos sin medicamentos más antiguos y más utilizados para la depresión y otros trastornos mentales.

- La ECT consiste en aplicar pequeñas cantidades de corriente eléctrica en uno o ambos lados del cerebro. De esa manera se cambia la forma en que trabajan las sustancias químicas del cerebro.
- La ECT se usa a menudo para tratar la depresión resistente a tratamiento.
- Una sesión de ECT dura entre 10 y 15 minutos y se realiza en un hospital o clínica. Se le administra al paciente anestesia; es decir, medicamentos que hacen que el paciente se duerma. La persona no está despierta durante la sesión de ECT.
- Una persona puede necesitar dos o tres sesiones por semana durante 2 a 4 semanas. El número de sesiones depende de la condición de la persona y de cuánto tiempo le tome sentirse mejor.

##### ¿Qué beneficios ofrece la ECT?

La ECT se ha utilizado durante muchos años para ayudar a las personas que padecen de depresión. Esta revisión no incluyó investigaciones sobre los beneficios de la ECT. Los investigadores consideran que la ECT tiene una máxima eficacia para ayudar a las personas con tendencias suicidas. En las personas mayores, la ECT parece ser tanto o más beneficiosa que en las personas más jóvenes.

##### ¿Cuáles son los efectos secundarios de la ECT?

- Algunas personas han tenido convulsiones después de la terapia ECT.
- Algunas investigaciones antiguas señalaban que las personas que reciben ECT pueden no pensar tan bien o con rapidez después de la terapia.
- La anestesia puede causar efectos secundarios, como presión arterial baja, problemas del corazón o reacciones alérgicas.
- Las personas con enfermedad cardiaca inestable, problemas de hemorragia o presión extra en el cráneo no deben recibir ECT.

##### ¿Qué otras cosas debo considerar?

- La ECT ha cambiado y ahora es más segura que cuando empezó a utilizarse. Muchas personas con diferentes tipos de enfermedades mentales se han tratado con ECT.
- Una sesión de ECT cuesta alrededor de $2,500, incluida la anestesia. Los costos pueden aumentar si es necesario pasar la noche en el hospital.
- La mayoría de los planes de seguro médico, así como Medicaid y Medicare, cubren los costos de la ECT. La cantidad que pague dependerá de su plan de seguro médico.

#### Estimulación magnética transcraneal repetitiva

En la estimulación magnética transcraneal repetitiva (rTMS, por su sigla en inglés) se utilizan imanes para estimular las células nerviosas del cerebro. Un aparato especial, que se coloca cerca de la parte superior de la cabeza, envía energía magnética hacia la parte delantera del cerebro, llamada “corteza prefrontal”. Esta parte del cerebro controla el estado de ánimo y la depresión.

Los imanes envían al cerebro un pulso que estimulan las células nerviosas. Los investigadores no han entendido del todo cómo funciona exactamente la rTMS, pero piensan que la energía magnética puede ayudar a mejorar la forma en que las células de la corteza se comunican entre sí.

La rTMS se usa para tratar la depresión, otras enfermedades mentales, la epilepsia y la enfermedad de Parkinson. La Food and Drug Administration (Administración de Alimentos y Medicamentos de los Estados Unidos; FDA por su sigla en inglés) no la ha aprobado para la depresión resistente a tratamiento, pero se ha utilizado en personas que no mejoraron después de probar con un medicamento durante 6 semanas o más.

- Las sesiones de tratamiento con rTMS se pueden realizar en un consultorio médico. La rTMS no requiere anestesia (medicamentos que lo hacen dormir). Usted permanece despierto durante la sesión.
- Las sesiones suelen durar alrededor de 40 minutos.
- El tratamiento con rTMS se administra todos los días (solamente de lunes a viernes) de 2 a 6 semanas. El número de semanas depende de la condición de la persona y de cuánto tiempo le tome sentirse mejor.

##### ¿Qué beneficios ofrece la rTMS?

- Las investigaciones encontraron que las personas que recibían rTMS tenían una probabilidad tres veces mayor de sentir cierto alivio de su depresión.
- Las investigaciones encontraron que las personas que recibían rTMS tenían una probabilidad seis veces mayor de que la depresión desapareciera totalmente. Los investigadores no confían tanto en este resultado, porque proviene solamente de pocos estudios.
- La rTMS puede mejorar la salud general de la persona y su capacidad para realizar sus actividades diarias, pero no existe suficiente investigación para poder afirmarlo con certeza.
- No existe la suficiente investigación para saber si la rTMS puede evitar que los síntomas de la depresión se repitan.

##### ¿Cuáles son los efectos secundarios de la rTMS?

- No existe suficiente investigación para saber qué probabilidad hay de que las personas experimenten efectos secundarios por el tratamiento con rTMS.
- En algunas personas, la rTMS puede causar dolor en el cuero cabelludo, pero no existe suficiente investigación para poder afirmarlo con certeza. Otros efectos secundarios pueden ser: dolor de cabeza leve, desmayos y cambios temporales de audición.

##### ¿Qué otras cosas debo considerar?

- La rTMS es un tratamiento más nuevo que otros tratamientos. Eso significa que en la zona donde usted vive puede no haber muchos lugares que tengan el equipo para este tratamiento.
- La rTMS no está aprobada para personas que tengan depresión resistente a tratamiento. Eso significa que la terapia de rTMS no está cubierta por Medicaid ni Medicare y puede no estar cubierta por su seguro médico. Es posible que usted tenga que pagar el costo total del tratamiento. Para la mayoría de las personas, el costo total promedio del tratamiento de rTMS está entre $2,000 y $7,500.
- No deben usar rTMS las personas con alto riesgo de convulsiones o que tengan en la cabeza implantes o metales sensibles a imanes.

#### Estimulación vagal o del nervio vago

Para la estimulación vagal, o VNS por su sigla en inglés, se implanta en el cuerpo, mediante cirugía, un dispositivo redondo que funciona con baterías. El aparato se coloca en el pecho y se conecta mediante un pequeño cable a un nervio del cuello llamado “nervio vago”.

Cada 5 minutos, el cable aplica en el nervio vago un impulso eléctrico que dura 30 segundos. Por lo general, se mantiene dentro del cuerpo durante 10 semanas o más, luego de lo cual se retira. Fue creado originalmente para personas con epilepsia, pero se usa también en las personas que padecen de depresión resistente a tratamiento.

- La VNS suele usarse solamente en personas que no han logrado alivio de la depresión después de haber probado con cuatro o más medicamentos para la depresión.
- La VNS se usa solamente en personas de 18 años de edad o más.
- La operación dura entre 30 y 60 minutos. Tal vez no se necesite pasar la noche en el hospital.

##### ¿Cuáles son los beneficios de la VNS?

- No existen suficientes estudios adecuados para saber qué tan bien funciona la VNS.
- Investigaciones limitadas encontraron que la VNS no mejoró los síntomas de depresión.

##### ¿Qué efectos secundarios causa la VNS?

- Algunas personas tuvieron cambios de la voz, tos, dolor de cuello, hormigueo o entumecimiento de la piel y dificultad para respirar.
- Ya que para administrar la VNS se requiere una operación, quienes reciben este tratamiento pueden tener también los problemas propios de una cirugía y anestesia (medicamentos para dormir al paciente).

##### ¿Qué otras cosas debo considerar?

- El dispositivo de VNS puede que permanezca mucho tiempo en el cuerpo.
- Pueden necesitarse de 6 a 12 meses para que la persona note los beneficios de la VNS.
- La terapia de VNS no está cubierta por Medicaid ni Medicare, y es posible que no la cubra su plan de seguro médico. Eso significa que tal vez deba usted pagar todo el costo. Para la mayoría de las personas, el costo promedio del tratamiento, sin contar el costo de la operación, está entre $10,000 y $20,000.

#### Psicoterapia o terapia de conversación

Los médicos pueden llamarla “terapia cognitivo-conductual” o “terapia interpersonal”. En inglés se conoce como “talk terapy”. Terapeutas capacitados hablan con la persona acerca de lo que piensa y siente respecto a su depresión. Lo que la persona y el terapeuta hablan ha sido cuidadosamente planificado por el terapeuta. La persona y el terapeuta pueden hablar sobre determinados síntomas o sucesos de la vida, sobre la forma de enfrentarlos o la manera de abordar los problemas. Cada sesión es parte de un programa más amplio de terapia destinado a ayudar a la persona a sentirse mejor.

- En general, la psicoterapia o terapia de conversación se realiza en sesiones de 30 minutos o una hora, una vez por semana durante 3 ó 4 meses, según el caso.
- Ciertas psicoterapias o terapias de conversación se hacen con un grupo de personas y el terapeuta, en vez de sólo con el terapeuta.

##### ¿Cuáles son los beneficios de la psicoterapia o terapia de conversación?

No existen suficientes estudios sobre la eficacia de la psicoterapia o terapia de conversación en los pacientes que tienen depresión resistente a tratamiento. La psicoterapia o terapia de conversación se ha estudiado en personas que padecen depresión, trastornos de la alimentación, ansiedad y trastornos de la personalidad.

##### ¿Cuáles son los efectos secundarios de la psicoterapia o terapia de conversación?

Las investigaciones no han encontrado efectos secundarios al usar la psicoterapia o terapia de conversación.

##### ¿Qué otras cosas debo considerar?

- La psicoterapia o terapia de conversación está cubierta por Medicare y la mayoría de los planes de seguro médico, aunque el número de sesiones cubiertas puede estar limitado. La cantidad que pague dependerá de su plan de seguro médico. La mayoría de los terapeutas cobran alrededor de $150 por sesión.
- Encontrar el terapeuta correcto para usted puede determinar el éxito de este tratamiento. Tal vez quiera considerar cómo se siente respecto al género (masculino o femenino), la edad, la raza o la personalidad del terapeuta. Los terapeutas están acostumbrados a que las personas tomen la decisión de seguirse atendiendo con ellos, después de la primera cita. Ellos no se ofenderán si usted encuentra a otro que le haga sentir con más confianza.

### ¿Cómo se comparan entre sí todas estas terapias?

Hay pocas investigaciones en las que se compare cada uno de estos tratamientos con los demás. Aunque los investigadores no tienen una certeza absoluta, algunos estudios encontraron que:

- La ECT parece funcionar mejor que un antidepresivo estándar para reducir o eliminar completamente los síntomas de depresión.
- No hay diferencias claras entre la eficacia de la ECT y la rTMS para reducir o eliminar los síntomas de depresión.
- No hay diferencias claras entre la ECT combinada con rTMS y la ECT por sí sola, en cuanto a la eficacia para reducir o eliminar los síntomas de depresión.
- Los investigadores no saben si una de las terapias tiene más efectos secundarios que las otras.
- Los investigadores no saben si la terapia de conversación brinda más beneficios que los medicamentos.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Usted y su médico pueden decidir juntos cuál es la mejor opción para usted, considerando:

- Otras condiciones de salud que puedan aumentar su riesgo de tener efectos secundarios.
- La naturaleza específica de su depresión y otras causas posibles para tener depresión resistente a tratamiento.
- Sus valores, preferencias y desagrados respecto a cada una de las opciones.
- Sus metas de tratamiento y recuperación de la depresión.
- Su seguro médico y los costos de cada opción para usted.

Si su depresión le dificulta hablar sobre estos temas, lleve a su consulta médica a un familiar o amigo de confianza.

### Hable con su médico o profesional de salud

Las siguientes son algunas preguntas que tal vez quiera hacerle a su médico o profesional de salud en su próxima visita.

- ¿Por qué tengo depresión resistente a tratamiento?
- ¿Seguiré estos tratamientos en vez de tomar medicamentos o debo seguir tomando mis medicamentos para la depresión?
- ¿Siente preocupación por mí con estos tratamientos, tomando en cuenta mi estado de salud?
- ¿Si una opción no funciona, cuál cree que sea la siguiente que debería probar?
- ¿Cuándo le debo avisar si el tratamiento está o no está funcionando?
- ¿Cuál es mi riesgo de tener efectos secundarios?

Escriba otras preguntas aquí:

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

Anote aquí las respuestas:

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

## Fuente

La información de este resumen proviene del informe Nonpharmacological Interventions for Treatment-Resistant Depression (Intervenciones no farmacológicas para la depresión resistente a tratamiento), de septiembre de 2011.

El informe fue producido por RTI International–University of North Carolina Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Carolina del Norte–RTI International) con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite http://www.effectivehealthcare.ahrq.gov/trd.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud). Esta página está disponible en http://www.nlm.nih.gov/medlineplus/spanish/medlineplus.html.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes con depresión.

Traducido de la publicación en inglés titulada Therapies for Treatment-Resistant Depression: A Review of the Research.