# Opciones de tratamiento para niños con testículos no descendidos

Revisión de la investigación para padres y personas que ayudan al cuidado

## ¿Es esta información apropiada para mí?

### Si cumple con todo lo siguiente, esta información es para usted

- El médico^*^ del niño le ha dicho que su hijo tiene uno o los dos testículos “no descendidos”. Esto sucede cuando uno o ambos testículos no bajan al escroto antes del nacimiento. El nombre médico de esta condición es “criptorquidia”.
- Usted quiere saber lo que han encontrado los investigadores respecto a las opciones de tratamiento para los testículos no descendidos.
- Su hijo aún no ha entrado en la pubertad. La información de este resumen proviene de investigaciones en niños antes de la pubertad.

### ¿Qué cubrirá este resumen?

Este resumen cubrirá:

- Lo que significa tener testículos no descendidos
- Opciones de tratamiento para los niños con testículos no descendidos
- Lo que han encontrado los investigadores respecto a la eficacia de los tratamientos
- Efectos secundarios posibles de los tratamientos

Este resumen puede ayudarle a hablar con el médico sobre qué tratamiento puede ser apropiado para su niño.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 60 estudios acerca de tratamientos para los testículos no descendidos publicados entre 1980 y febrero de 2012. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/undescended-testicle.cfm (disponible sólo en inglés).

## Conozca la condición de su hijo

### ¿Qué son los testículos no descendidos?

Los testículos son los dos pequeños órganos redondos, alojados dentro del escroto (bolsa de piel situada debajo del pene), que elaboran las hormonas masculinas y el esperma. La condición conocida como “testículo no descendido” ocurre cuando uno o ambos testículos del niño no bajan al escroto antes del nacimiento. Esta condición se llama también “criptorquidia”.

Cuando un bebé varón se desarrolla en el útero de su madre, los testículos se forman en el abdomen (barriga) del pequeño. Poco antes del nacimiento, los testículos descienden al escroto.

En algunos bebés, uno o ambos testículos no bajan como deben. Los testículos no descendidos pueden estar en la región del abdomen o de la ingle. También es posible que un bebé nazca sin uno o ambos testículos. Los testículos no descendidos pueden estar sanos y funcionar normalmente. Sin embargo, a veces los testículos no descendidos no se desarrollan correctamente y no funcionan como deben.

Los médicos no saben qué causa los testículos no descendidos. Pero, no son causados por algo que la madre haya hecho durante el embarazo.

En 7 de cada 10 bebés nacidos con testículos no descendidos, los testículos bajarán a su posición correcta antes de que el bebé tenga 6 meses de edad. Si los testículos del niño no han bajado en ese tiempo, es importante que hable con el médico del niño respecto a las opciones de tratamiento.

### ¿Que tan frecuentes son los testículos no descendidos?

- De cada 100 bebés varones nacidos a término, 3 nacen con testículos no descendidos.
- De cada 100 niños varones nacidos prematuramente (antes del término), hasta 30 nacen con testículos no descendidos.
- De cada 100 niños con testículos no descendidos, hasta en 5 no se encuentra el testículo no descendido.

### ¿Qué problemas podría causar un testículo no descendido?

Un testículo que no baja a su lugar correcto en el escroto puede dañarse. Esto podría ocasionar infertilidad (no poder tener hijos) más adelante en la vida u otros problemas médicos.

Los hombres que han tenido testículos no descendidos (uno o ambos, ya sea que se hayan tratado o no) pueden tener mayor riesgo de cáncer testicular. Es importante que los hombres y adolescentes varones que han tenido esta condición se examinen los testículos cada mes, para buscar pequeños bultos u otros signos de tumores o problemas.

## Conozca sus opciones

### ¿Cómo se tratan los testículos no descendidos?

El objetivo del tratamiento es hacer que los testículos bajen a su lugar correcto dentro del escroto. Si el testículo del niño no ha descendido para cuando cumpla 6 meses de edad, deberá hablar con el médico del niño respecto a las opciones de tratamiento. Es probable que el médico recomiende la cirugía. En ciertos casos, el tratamiento hormonal puede ser una opción.

Lo mejor es tratar los testículos no descendidos cuando el niño es aún de muy corta edad (tiene entre 6 meses y 1 año de edad).

### Cirugía

Es probable que el médico del niño sugiera cirugía (orquiopexia u orquiopexia FS) para hacer que baje al escroto el testículo no descendido.

- Orquiopexia: Si el testículo no descendido está en la parte baja del abdomen o en la ingle, se le puede mover al escroto mediante una operación llamada “orquiopexia”.
- Orquiopexia FS: Si el testículo no descendido se encuentra en la parte alta del abdomen, los vasos sanguíneos conectados a él pueden no ser lo suficientemente largos para llegar al escroto. En ese caso, el cirujano necesitará hacer un tipo diferente de cirugía. Esta operación se llama orquiopexia de “Fowler-Stephens” (o FS). Puede hacerse de dos maneras:
  - Cirugía de una etapa: una sola operación
  - Cirugía de dos etapas: dos operaciones distintas, con un intervalo entre ambas de por lo menos 6 meses

#### Cirugía abierta o cirugía laparoscópica

La orquiopexia y la orquiopexia FS se pueden hacer como cirugía abierta o cirugía laparoscópica (abajo se describe cada una). Si el testículo no descendido del niño está en la ingle, el cirujano hará cirugía abierta. Si el cirujano no está seguro de dónde está el testículo o no puede encontrarlo, se puede hacer cirugía laparoscópica para ver si está en el abdomen. Si el testículo se encuentra en el abdomen, el cirujano puede optar entre cirugía abierta y laparoscópica para hacerlo bajar al escroto.

- Cirugía abierta: Para la operación, el cirujano hace un corte en el abdomen o la ingle y en el escroto.
- Cirugía laparoscópica: En esta operación, el cirujano utiliza un instrumento llamado laparoscopio. El laparoscopio es un tubo delgado con una videocámara diminuta que el cirujano introduce en el abdomen a través de unos cortes pequeños, además de otros instrumentos pequeños, para hacer la operación. El laparoscopio permite al cirujano ver por dentro del cuerpo del niño para realizar la operación sin tener que hacer cortes grandes.

El tipo de cirugía que necesita su hijo depende de la ubicación del testículo no descendido. El médico del niño puede decirle qué tipo de cirugía necesita.

Ubicación del testículo no descendido: | Tipo de cirugía:
Ingle | Orquiopexia abierta
Parte baja del abdomen | Orquiopexia abierta o laparoscópica
Parte alta del abdomen | Orquiopexia FS de una etapa, abierta o laparoscópica o bien Orquiopexia FS de dos etapas, abierta o laparoscópica

### ¿Qué han encontrado los investigadores sobre la eficacia de la cirugía para tratar los testículos no descendidos?

Los investigadores encontraron que la cirugía es eficaz para hacer bajar al escroto los testículos no descendidos. Sin embargo, en ocasiones el testículo puede dañarse durante la cirugía, de tal modo que deje de funcionar.

El diagrama siguiente muestra la eficacia de cada tipo de cirugía. También muestra con qué frecuencia los testículos se dañan en cada tipo de cirugía.

Tipo de cirugía: | Este tipo de operación se hace cuando: | Esta operación es eficaz en: | Los testículos se dañan durante este tipo de cirugía en:
Orquiopexia | El testículo no descendido está en la parte baja del abdomen o en la ingle y los vasos sanguíneos tienen la longitud suficiente para llegar al escroto | 96 de 100 niños | 2 de 100 niños
Orquiopexia FS de una etapa † | El testículo no descendido está en la parte alta del abdomen y los vasos sanguíneos no tienen la longitud suficiente para llegar al escroto | 78 de 100 niños | 28 de 100 niños^*^
Orquiopexia FS de dos etapas † | El testículo no descendido está en la parte alta del abdomen y los vasos sanguíneos no tienen la longitud suficiente para llegar al escroto | 86 de 100 niños | 8 de 100 niños^*^
Los investigadores encontraron también que:
La cirugía abierta y la cirugía laparoscópica parecen ser igual de eficaces para tratar los testículos no descendidos que se encuentran en el abdomen, pero se necesita mayor investigación para saberlo con certeza.

† No existe suficiente investigación que compare la orquiopexia FS de una etapa con la de dos etapas para saber cuál puede ser más eficaz.

* Se necesita más investigación para saberlo con certeza.

### ¿Cuáles son los posibles efectos secundarios de la cirugía para tratar los testículos no descendidos?

La cirugía para tratar los testículos no descendidos suele ser segura y las complicaciones son raras. Pero cualquier tipo de cirugía conlleva efectos secundarios posibles; por ejemplo:

- Sangrado
- Infección
- Lesión de vasos sanguíneos
- Lesión de algún órgano (como los testículos, los cordones espermáticos conectados a cada testículo, la vejiga u otros)
- Riesgos de la anestesia general, como neumonía, ataque al corazón o derrame, aunque son raros

También es posible que el testículo regrese a la ingle o al abdomen después de la cirugía. Si eso sucede, podría requerirse otra operación para volver a bajar el testículo o para extirparlo.

### ¿La cirugía para tratar los testículos no descendidos afectará la fertilidad de mi hijo?

En general, los hombres que fueron operados en la niñez para tratar un testículo no descendido no tienen problemas de fertilidad (la capacidad de tener hijos). Los hombres que fueron operados en la niñez para tratar dos testículos no descendidos tienen mayor probabilidad de tener problemas de fertilidad que los hombres con sólo un testículo no descendido.

#### Tratamiento hormonal

El tratamiento hormonal es otra opción para tratar los testículos no descendidos en ciertos casos, pero se utiliza muy poco. Si el testículo del niño está cerca del escroto, el médico puede sugerir el tratamiento hormonal en un intento por hacer que el testículo baje. La hormona que se utiliza se llama hCG (gonadotropina coriónica humana). La hormona viene en una inyección que el médico aplica al niño entre dos y cuatro veces a la semana, durante 4 semanas o más.

### ¿Qué han descubierto los investigadores sobre la eficacia del tratamiento hormonal?

Los investigadores encontraron que el tratamiento hormonal con hCG puede ser un poco más eficaz que el no recibir ningun tratamiento hormonal cuando los testículos de los niños están cerca del escroto. Sin embargo, se necesita mas investigación para saber con certeza si el tratamiento hormonal es eficaz. Aun cuando este tratamiento resulte eficaz, es posible que el testículo regrese a la ingle o el abdomen. No existe suficiente investigación para saber con qué frecuencia ocurre esto.

Nota: Si el tratamiento hormonal no da resultado o si el testículo está lejos del escroto, el médico probablemente recomiende la cirugía para hacer bajar el testículo no descendido al escroto.

Si su hijo tiene una hernia (cuando parte del intestino o de la grasa del abdomen sobresale por una abertura en los músculos de la ingle), junto con el testículo no descendido, es posible que necesite cirugía.

### ¿Qué efectos secundarios puede tener el tratamiento hormonal?

Los efectos secundarios posibles del tratamiento hormonal con hCG en el caso de los testículos no descendidos se enumeran a continuación. No todos los niños que se traten con hCG tendrán efectos secundarios. Los efectos secundarios suelen desaparecer al terminar el tratamiento. Sin embargo, los investigadores no saben si el tratamiento hormonal puede ocasionar otros problemas en la edad adulta, como no poder tener hijos.

- Dolor de cabeza
- Irritabilidad
- Inquietud
- Depresión
- Cansancio
- Hinchazón de las piernas, los tobillos y los pies
- Crecimiento de los senos
- Agrandamiento del pene
- Crecimiento del vello púbico o axilar
- Erecciones
- Conducta agresiva
- Dolor en el área donde se aplicó la inyección

### ¿Cuáles son los costos de los tratamientos para los testículos no descendidos?

Los costos para usted de la cirugía o los tratamientos hormonales dependen de su seguro médico.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Al decidir qué tratamiento sería el mejor para su niño, se deben considerar muchos factores. Tal vez quiera hablar con el médico del niño sobre:

- Si la cirugía o el tratamiento hormonal podrían servirle al niño
- Los beneficios y efectos secundarios posibles del tratamiento
- Los costos del tratamiento

### Pregunte a su médico

- ¿Qué pasaría si mi hijo no recibe ningún tratamiento?
- ¿A qué edad debe mi hijo recibir tratamiento?
- ¿Cuál es la mejor opción de tratamiento para mi hijo?
- Si operan a mi hijo, ¿qué tipo de cirugía necesitará?
- ¿Sería mejor la cirugía abierta o la laparoscópica para mi hijo?
- ¿A qué efectos secundarios posibles debo estar atento?
- ¿Cómo trataremos algún efecto secundario que se le presente a mi hijo?
- ¿Cuánto tiempo tardará mi hijo en recuperarse de la cirugía?
- ¿Qué actividades debe evitar mi hijo inmediatamente después de la cirugía?

## Fuente

La información de este resumen proviene del informe Evaluation and Treatment of Cryptorchidism (Evaluación y tratamiento de la criptorquidia), de diciembre de 2012. Fue producido por el Vanderbilt Evidence-Based Practice Center (Centro de Práctica Basada en la Evidencia de Vanderbilt), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Si desea una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/undescended-testicle.cfm (disponible sólo en inglés).

Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por padres o proveedores de atención de niños con testículos no descendidos.

Esta guía fue traducida de la publicación en inglés titulada Treatment Options for Children With Undescended Testicles: A Review of the Research for Parents and Caregivers.

* En este resumen, el término “médico” se refiere al profesional de la atención médica de su niño, como su pediatra, urólogo pediatra (médico que atiende a niños con trastornos en los genitales o las vías urinarias), cirujano, enfermera o asistente médico.